# Analytical Framework

Appendix Table D1 Algorithm to define eligibility of studies

### Research Question 1 What constitutes an adequate diagnostic evaluation in the primary care setting on which to base treatment of UI?

#### Verification/Selection of Study Eligibility

##### Criteria 1 - Confirm eligibility of the target population

Eligible descriptors:

Adult women in the community | Yes | No | Combined
Elderly women in the community | Yes | No | Combined

If NO – exclude

##### Criteria 2 - Confirm eligibility of the outcomes

Eligible descriptors:

Diagnosis of urinary incontinence | Yes | No | Combined
Incidence of urinary incontinence | Yes | No | Combined

If NO – exclude

##### Criteria 3 - Confirm eligibility of diagnostic strategies

Questionnaire

Scale

Diary

Interview

Pad test

Multichannel urodynamics

If NO – exclude

##### Criteria 4 – Confirm eligibility of the outcomes assessment

Eligible descriptors:

True positive | Yes | No
True negative | Yes | No
False positive | Yes | No
False negative | Yes | No
Sensitivity | Yes | No
Specificity | Yes | No
Positive predictive likelihood of the test | Yes | No
Validity of the scale | Yes | No
Validity of the questionnaire | Yes | No
Reliability of the scale | Yes | No
Reliability of the questionnaire | Yes | No

If NO for all descriptors – exclude

##### Criteria 5. Confirm eligible level of evidence

Eligible descriptors:

Randomized controlled clinical trials | Yes | No
Multicenter controlled clinical trials | Yes | No
Large (>100 subjects) observational studies | Yes | No
Case-control studies with >10 cases | Yes | No

If NO for all descriptors – exclude

### 2–3 How effective is the pharmacologic treatment of UI? How effective is the nonpharmacologic treatment of UI?

#### Verification/Selection of Study Eligibility

##### Criteria 1 - Confirm eligibility of the target population

Eligible descriptors:

Adult women with urinary incontinence in the community | Yes | No | Combined
Elderly women with urinary incontinence in the community | Yes | No | Combined

If NO – exclude

##### Criteria 2 – Confirm eligibility of the outcomes

Eligible descriptors:

Prevalence of urinary incontinence/types | Yes | No | Combined
Progression of urinary incontinence/types | Yes | No | Combined
Improvement in urinary incontinence/types | Yes | No | Combined
Continence | Yes | No | Combined
Changes in severity or frequency of urinary incontinence/types | Yes | No | Combined
Quality of life related to urinary incontinence/types | Yes | No | Combined
Adverse events | Yes | No | Combined

If NO – exclude

##### Criteria 3 – Confirm eligibility of interventions

Eligible drugs and nonpharmacologic treatments

If NO – exclude

##### Criteria 4 – Confirm eligible level of evidence

Eligible descriptors for clinical outcomes:

Randomized controlled clinical trials | Yes | No
Multicenter controlled clinical trials | Yes | No
Large (>100 subjects) observational studies | Yes | No

If No for all descriptors – exclude

If adverse events reported – include

Appendix Table D2 Definitions of population, interventions, comparators, outcomes, and settings (PICOS) framework

Population(s):
For KQ1. Adult and elderly women with symptoms of UI.
For KQ2 and KQ3. Adult and elderly women with diagnosed UI.
Interventions:
For KQ1 about diagnostic methods, the method that was defined as the gold standard
Gold standard
Multichannel urodynamics
Bladder diary

For KQ2 and KQ3 about treatments for urinary incontinence

Variable | Definition
Health education | Education that increases the awareness and favorably influences the attitudes and knowledge relating to the early detection and prevention of urinary incontinence
Behavioral therapy | The application of behavioral changes to detect and manage incontinence, including: education about urinary structure and function; development of individualized diaries of daily dietary, physical activities, urinary habits; pelvic floor muscle exercises; voiding schedules: prompted, timed, habit retraining, patterned urge response toileting
Biofeedback | Process by which a person uses biofeedback information to gain voluntary control over the function of pelvic floor muscles and urination process
Pelvic floor muscle training for urinary incontinence | A systematic program of pelvic floor muscle exercises (Kegel exercises) designed to improve the strength and coordination of the pelvic floor muscles in order to improve urinary sphincter function and to control urgency
Vaginal cones | Insertion of vaginal cone (weighted device) into the vagina and contraction of the pelvic floor muscles in an effort to hold the device in place
Electrical stimulation | Application of electric current in treatment without the generation of perceptible heat Using low-voltage electric current to stimulate the correct group of muscles by using an anal or vaginal probe for delivery
Urethral plugs and patches | Insertion of plastic shapes into the urethra to stop the flow of urine or placed externally at the urinary meatus to prevent urine leakage; used for female stress urinary incontinence
Pessaries | A plastic or silicone device that is inserted into the vagina to provide support to the uterus, vagina, bladder, or rectum when there is pelvic organ prolapse; special pessaries with knobs are available to treat urinary incontinence
Magnetic stimulation | Stimulation with a brief magnetic field on the pelvic floor muscles and sacral roots without insertion of an anal or vaginal probe
Urethral bulking: Transurethral or periurethral injection techniques for women | Artificially inflating the submucosal tissues of the bladder neck;FDA-approved urethral bulking agents include collagen (Contigen^®^), autologous fat, and carbon bead particles (Durasphere^®^).
Topical estrogen therapy | Topical vaginal administration of estrogen
Pharmacological interventions | Ditropan^®^ (oxybutynin chloride) Sanctura^®^ (trospium chloride) Enablex^®^ (darifenacin) Vesicare^®^ (solifenacin succinate) Fesoterodine Tolterodine
Other tested pharmaceuticals | Propiverine Botulinum toxin injections Tricyclic antidepressants Imipramine hydrochloride

Devices that have been examined in women with urinary incontinence available at http://www.fda.gov/MedicalDevices/DeviceRegulationandGuidance/GuidanceDocuments/ucm070852.htm

Classification (21 CFR) | Class | Product Code | Description
Gastroenterology-Urology Devices
876.5270 Implanted electrical urinary continence device | III | EZT | Pacemaker, bladder
III | EZW | Stimulator, electrical, implantable, for incontinence
876.5280 Implanted mechanical/hydraulic urinary continence device | III | EZY | Device, incontinence, mechanical/hydraulic
| III | LNM | Agent, bulking, injectable for gastro-urology use
| III | OCK | Transurethral occlusion insert, urinary incontinence-control, female
Classification (21 CFR) | Class | Product Code | Description
Gastroenterology-Urology Devices
876.5310 Nonimplanted, peripheral electrical continence device | II | NAM | Stimulator, peripheral nerve, nonimplanted, for pelvic floor dysfunction
876.5320 Nonimplanted electrical continence device | II | KPI | Stimulator, electrical, nonimplanted, for incontinence
876.5920 Protective garment for incontinence | I 510(k) Exempt | EYQ | Garment, protective, for incontinence
N/A | Unclassified | MNG | External urethral occluder, urinary incontinence-control, female
Obstetrical and Gynecological Devices
884.1425 Perineometer | II | HIR | Perineometer
884.3575 Vaginal pessary | II | HHW | Pessary, vaginal

### Comparator

For KQ1 about diagnostic methods, the index methods that were tested

Questionnaires
Checklists and scales
Self-reported UI during a clinical examination
Provocation stress test
Frequency volume chart
Pad tests
Paper towel test
Ultrasound

For KQ2 and KQ3 about treatments

Efficacy | Placebo, no active treatment, or regular care
Comparative effectiveness | Active pharmacological treatment, education, behavioral therapy, biofeedback, bladder retraining (Kegel exercises), electrical stimulation, pads, and urethral plugs and pessaries in women

### Outcomes

Outcomes for KQ1 about diagnostic methods
- True positive for any, stress, and urgency incontinence
- True negative for any, stress, and urgency incontinence
- False positive for any, stress, and urgency incontinence
- False negative for any, stress, and urgency incontinence
- Sensitivity for any, stress, and urgency incontinence
- Specificity for any, stress, and urgency incontinence
- Positive predictive likelihood ratio for any, stress, and urgency incontinence

Primary outcomes after treatments (clinical outcomes)
- Continence
- Quality of life: measured by using a validated generic or condition-specific measure of quality of life developed to address issues related specifically to UI

Secondary outcomes | Definition
Remission of incontinence | Diminution of symptoms and signs of incontinence
Contained incontinence | Urine contained with pads or appliances
Dependent continence | Dry with toileting assistance, behavioral treatment, and/or medications
Independent continence | Dry, not dependent on ongoing treatment
Symptoms of incontinence1,2 | The subjective indicator of incontinence or change in its severity, as perceived by the patient, caregiver, or partner, and may lead her to seek help from health-care professionals
Signs of incontinence | Observed by the physician, including simple means, to verify symptoms and quantify them
Urodynamic observations | Observations made during urodynamic studies that have a number of possible underlying causes and do not represent a definitive diagnosis of a disease
Measures of the frequency, severity, and impact of urinary incontinence2
Micturition time chart | Records of times of micturitions (day and night) for at least 24 hours
Frequency volume chart (FVC) | Records of volumes voided and the time of each micturition (day and night) for at least 24 hours
Bladder diary | Records of times of micturitions, voided volumes, incontinence episodes, pad usage, and other information, such as fluid intake, the degree of urgency, and the degree of incontinence
Daytime frequency | The number of voids recorded during waking hours, including the last void before sleep and the first void after waking and rising in the morning
24-hour frequency | The total number of daytime voids and episodes of nocturia during a specified 24-hour period
24-hour production | All urine produced during 24 hours
Maximum voided volume | The largest volume of urine voided during a single micturition, as determined either from the frequency/volume chart or the bladder diary
Pad testing | The amount of urine lost during incontinence episodes (comparison of a short provocative test to a 24-hour pad test)
Improvement in incontinence | Reduction frequency and severity of incontinence episodes Reduction in restrictions of daily activities due to incontinence
Progression of incontinence | Increase in frequency and severity of incontinence episodes Increase in restrictions of daily activities because of incontinence Continence not achieved No reduction in the frequency and severity of incontinent episodes

### Harms

Adverse events resulting from drugs

Adverse events resulting from nonpharmacological treatments

### Settings

Primary care clinic

Specialized clinic (nurse practitioners)

Cointerventions as reported in the studies

### Definition of Terms

The first step is to define what is meant by the term “incontinence,” which has many different implications for different groups of patients. Treating incontinence as a universal construct may impede understanding of the condition and its treatment. For example, incontinence in younger women occurs most likely because of pelvic floor failure, whereas in frail older persons it is often the result of problems with mobility or intellectual performance.

Definitions of urinary incontinence

Variable | Definition
Symptoms of urinary incontinence2 | Any involuntary leakage of urine
Signs of urinary incontinence | Urine leakage seen during physical examination; this leakage may be urethral or extraurethral
Extra-urethral incontinence | Urine leakage occurring through channels other than the urethra
Uncategorized incontinence | Involuntary urine leakage that cannot be classified into any of the categories listed above on the basis of signs and symptoms
Transient urinary incontinence3,4 | Potentially reversible incontinence resulting from conditions that may resolve if the underlying cause is managed: delirium/confusional state; urinary tract infection (symptomatic); atrophic urethritis/vaginitis; use of pharmaceuticals; psychological conditions, especially depression; excessive urine output related to another medical condition (e.g., congestive heart failure, hyperglycemia); restricted mobility; stool impaction
Established urinary incontinence3,4 | Urinary incontinence that is attributed to bladder or urethral dysfunction, such as: detrusor overactivity; detrusor underactivity; urethral obstruction; urethral incompetence
Stress urinary incontinence | Involuntary urine leakage on physical exertion or effort or with sneezing or coughing
Urgency UI5 | Involuntary leakage accompanied by or immediately preceded by urgency
Overflow incontinence6 | Urinary incontinence associated with: bladder overdistention; a contractile detrusor; hypotonic or underactive detrusor, occurring secondarily to drugs, fecal impaction, diabetes, lower spinal cord injury, or disruption of the motor innervation of the detrusor muscle
Mixed urinary incontinence1,2 | Involuntary leakage associated with urgency and also with exertion, effort, sneezing, or coughing
Situational urinary incontinence | Incontinence during sexual intercourse or when giggling
Continuous urinary leakage | Continuous urinary leakage
Acute incontinence7 | Sudden onset of symptoms related to an illness, treatment, or medication
Chronic incontinence | Persistent urinary incontinence, including disorders of storage (stress and urgency) and of emptying (overflow) and functional and mixed incontinence
Severity of incontinence | Measured as incontinent episodes/unit time; pad changes/unit time; pad weight/unit time; number of micturitions/unit time; urine loss on a pad test Also indicated by urodynamically diagnosed detrusor overactivity; urodynamic stress incontinence
Sandvik’s severity index8 | Multiplied reported frequency (4 levels) by the amount of leakage (2 levels).
Slight incontinence | Leakage of drops a few times a month (~6 g/24 hours, 95% confidence interval 2–9)
Moderate incontinence | Daily leakage or drops (~17 g/24 hours, 95% confidence interval 13–22)
Severe incontinence | Leakage of large amount of urine at least once a week (~56 g/24 hours, 95% confidence interval 44–67)

We prioritized clinical outcomes and measure of quality of life following the FDA guideline for UI9

Endpoint | Potential Advantages | Potential Disadvantages
1-Hour Pad Weight Test(Amount of urine leakage experienced by the subject in 1 hour during a standardized series of activities or exercises in the investigator’s office)2 | * Objective | * Outcomes other than dryness may not be meaningful to patients
1-Hour Pad Weight Test(Amount of urine leakage experienced by the subject in 1 hour during a standardized series of activities or exercises in the investigator’s office)2 | * Standardized | * Not correlated with patients’ daily activities
1-Hour Pad Weight Test(Amount of urine leakage experienced by the subject in 1 hour during a standardized series of activities or exercises in the investigator’s office)2 | * Assesses severity of urine leakage | * Poor to moderate sensitivity
1-Hour Pad Weight Test(Amount of urine leakage experienced by the subject in 1 hour during a standardized series of activities or exercises in the investigator’s office)2 | | * Subject to variability
24-Hour Pad Weight Test(Amount of urine leakage experienced by the subject at home during a 24-hour period; all pads used during the test period are weighed before and after use) | * Objective | * Outcomes other than dryness may not be meaningful to patients
24-Hour Pad Weight Test(Amount of urine leakage experienced by the subject at home during a 24-hour period; all pads used during the test period are weighed before and after use) | * Correlated with patients’ daily activities | * Less standardized
24-Hour Pad Weight Test(Amount of urine leakage experienced by the subject at home during a 24-hour period; all pads used during the test period are weighed before and after use) | * High sensitivity | * Subject to variability
24-Hour Pad Weight Test(Amount of urine leakage experienced by the subject at home during a 24-hour period; all pads used during the test period are weighed before and after use) | * Assesses severity of urine leakage | * Requires patient compliance
Number of Incontinence Episodes/Day(Obtained using a voiding diary) | * Objective | * May not directly correlate with the severity of urine leakage
Number of Incontinence Episodes/Day(Obtained using a voiding diary) | * Meaningful to patients | * Less standardized
Number of Incontinence Episodes/Day(Obtained using a voiding diary) | * Correlated with patients’ daily activities | * Subject to variability
Number of Incontinence Episodes/Day(Obtained using a voiding diary) | | * Requires patient compliance
Number of Pads Used/Day(Obtained using a voiding diary) | * Objective | * May not directly correlate with the severity of urine leakage
Number of Pads Used/Day(Obtained using a voiding diary) | * Meaningful to patients | * Less standardized
Number of Pads Used/Day(Obtained using a voiding diary) | * Correlated with patients’ daily activities | * Subject to variability
Number of Pads Used/Day(Obtained using a voiding diary) | | * Requires patient compliance
Quality of Life(Assessed using a validated questionnaire) | * Meaningful to patients | * Significant placebo effect
Quality of Life(Assessed using a validated questionnaire) | * Standardized | * Subjective
Quality of Life(Assessed using a validated questionnaire) | * Patient’s daily activities taken into account | * Subject to variability; * Not correlated with the severity of urine leakage
Urodynamics Measure(Measurement such as leak point pressure, cystometric outcome, etc.) | * Objective | * Not Meaningful to patients
Urodynamics Measure(Measurement such as leak point pressure, cystometric outcome, etc.) | * Standardized | * Not correlated with patients’ daily activities
Urodynamics Measure(Measurement such as leak point pressure, cystometric outcome, etc.) | * Less subject to variability

Appendix Table D3 Refinement of the questions following PICOS framework

Question | Population | Intervention (Independent Variable) | Comparator | Outcomes (dependent variables) | Settings
What constitutes an adequate diagnostic evaluation on which to base treatment of UI? Are there validated tools to distinguish stress from urge incontinence in primary care? Do validated tools to distinguish stress from urge incontinence in primary care make a clinical difference in response to treatment? | Adult and elderly women with symptoms of UI | Questionnaires Checklists and scales Self reported UI during clinical exam Provocation stress test Frequency volume chart Pad tests Paper towel test Ultrasound | Gold standard: multichannel urodynamics; Diary | Diagnostic value of the tests, validity of questionnaires for any, stress, urgency, mixed UI Patient outcomes | Primary Care Specialized on UI clinic (nurse practitioners)
How effective is pharmacologic treatment of UI? Do medication interventions with their adverse drug reactions make QoL sense vs. pads? Do medications have evidence of clinical benefit in the treatment of patients with incontinence? Are there clinical predictors of response to the (above) interventions? | Adult and elderly women with diagnosed UI Patient adherence and overcoming of barriers Clinical predictors of the effects : Patient age, comorbities, baseline disease/condition for UI | Detrol (tolterodine tartrate), Ditropan (oxybutynin chloride), Sanctura (trospium chloride), Enablex (darifenacin), and Vesicare (solifenacin succinate).; - Other tested therapy: botulinum toxin injections, tricyclic antidepressant imipramine hydrochloride | Placebo [underlined: Comparative effectiveness with:] Active pharmacological treatment Education Behavioral therapy Biofeedback Bladder retraining (“Kegel exercises”) Electrical stimulation Pads Urethral “plugs” and pessaries in females | Continence Quality of life Improvement in frequency and severity of incontinence Adverse effects Differences in outcomes among subgroups of patients with different categories of the predictor (interaction models) Level of outcomes in subgroups of patients with different levels of predictors (subgroup analyses) | Primary Care Specialized on UI clinic (nurse practitioners)
How effective is non-pharmacologic treatment of UI? Do any of the following have evidence of clinical benefit in the treatment of patients with incontinence: Kegel exercises Minimally invasive techniques (e.g. collagen injection, etc.) Pessary Are there clinical predictors of response to the (above) interventions? | Adult and elderly women with diagnosed UI Patient adherence and overcoming of barriers Clinical predictors of the effects : Patient age, comorbities, baseline disease/condition for UI | Education Behavioral therapy Biofeedback Bladder retraining (“Kegel exercises”) External electrical stimulation (tibial nerve stimulation Urethral “plugs” and pessaries in females Collagen injection devices | No active treatment [underlined: Comparative effectiveness with:] Pharmacological treatment Other nonpharmacological treatments | Continence Quality of life Improvement in frequency and severity of incontinence Adverse effects Differences in outcomes among subgroups of the patients with different categories of the predictor (interaction models) Level of outcomes in subgroups of patients with different levels of predictors (subgroup analyses) | Primary Care Specialized on UI clinic (nurse practitioners)

Appendix Table D4 Pharmacological treatments for UI9

Drug Name | Active Ingredients | Dose | Dosage Form/Route
Labeled for UI
DETROL | TOLTERODINE TARTRATE | 1MG | TABLET; ORAL
DETROL | TOLTERODINE TARTRATE | 2MG | TABLET; ORAL
DETROL LA | TOLTERODINE TARTRATE | 2MG | CAPSULE, EXTENDED RELEASE; ORAL
DETROL LA | TOLTERODINE TARTRATE | 4MG | CAPSULE, EXTENDED RELEASE; ORAL
OXYTROL | OXYBUTYNIN | 3.9MG/24HR | FILM, EXTENDED RELEASE; TRANSDERMAL
GELNIQUE | OXYBUTYNIN CHLORIDE | 10%(100MG/PACKET) | GEL; TRANSDERMAL
DITROPAN XL | OXYBUTYNIN CHLORIDE | 5MG | TABLET, EXTENDED RELEASE; ORAL
DITROPAN XL | OXYBUTYNIN CHLORIDE | 10MG | TABLET, EXTENDED RELEASE; ORAL
DITROPAN XL | OXYBUTYNIN CHLORIDE | 15MG | TABLET, EXTENDED RELEASE; ORAL
DITROPAN | OXYBUTYNIN CHLORIDE | 5MG | TABLET; ORAL
SANCTURA | TROSPIUM CHLORIDE | 20MG | TABLET; ORAL
SANCTURA XR | TROSPIUM CHLORIDE | 60MG | CAPSULE, EXTENDED RELEASE; ORAL
ENABLEX | DARIFENACIN HYDROBROMIDE | EQ 7.5MG BASE | TABLET, EXTENDED RELEASE; ORAL
ENABLEX | DARIFENACIN HYDROBROMIDE | EQ 15MG BASE | TABLET, EXTENDED RELEASE; ORAL
VESICARE | SOLIFENACIN SUCCINATE | 5MG | TABLET; ORAL
VESICARE | SOLIFENACIN SUCCINATE | 10MG | TABLET; ORAL
TOVIAZ | FESOTERODINE FUMARATE | 4MG | TABLET, EXTENDED RELEASE; ORAL
TOVIAZ | FESOTERODINE FUMARATE | 8MG | TABLET, EXTENDED RELEASE; ORAL
Off label use
BOTOX | Botulinum Toxin Type A | 100U/VIAL | VIAL; SINGLE-USE
CYMBALTA | DULOXETINE HYDROCHLORIDE | EQ 20MG BASE | CAPSULE, DELAYED REL PELLETS; ORAL
CYMBALTA | DULOXETINE HYDROCHLORIDE | EQ 30MG BASE | CAPSULE, DELAYED REL PELLETS; ORAL
CYMBALTA | DULOXETINE HYDROCHLORIDE | EQ 60MG BASE | CAPSULE, DELAYED REL PELLETS; ORAL
IMIPRAMINE HYDROCHLORIDE | IMIPRAMINE HYDROCHLORIDE | 50MG | TABLET; ORAL
PREMARIN | ESTROGENS, CONJUGATED | 0.625MG/GM | CREAM; TOPICAL, VAGINAL
SYNTHETIC CONJUGATED ESTROGENS A | ESTROGENS, CONJUGATED SYNTHETIC A | 0.625MG/GM | CREAM; VAGINAL

Pharmacological classification of the drugs for UI that was used by the l4th International Consultation on Incontinence18 served as a guide to synthesize comparative effectiveness and harms from available treatments.

Drug therapy for stress urinary incontinence 18

SEROTONIN-NORADRENALINE

UPTAKE INHIBITORS

Duloxetine

Imipramine

ESTROGENS

Estrogen topical

Drugs used in the treatment of OAB/DO1:

Antimuscarinic drugs

Tolterodine

Trospium

Solifenacin

Darifenacin

Fesoterodine

Propantheline

Drugs with mixed actions

Oxybutynin

Propiverine; Flavoxate

Appendix Table D5 Data synthesis

For question 1 we calculated diagnostic values of different tests to diagnose incontinence:

Sensitivity=TP/(TP+FN)

Specificity=TN/(FP+TN)

Prevalence=(TP+FN)/(TP+FN+FP+TN)

Predictive value positive=TP/(TP+FP)

Positive predictive likelihood ratio:

LR + = (probability of an individual with the condition having a positive test)/(probability of an individual without the condition having a positive test)

LR + = (sensitivity)/(1 - specificity)

Clinical interpretations of likelihood ratios10

LR | Interpretation
> 10 | Large and often conclusive increase in the likelihood of disease
5 – 10 | Moderate increase in the likelihood of disease
2 – 5 | Small increase in the likelihood of disease
1 – 2 | Minimal increase in the likelihood of disease
1 | No change in the likelihood of disease
0.5 – 1.0 | Minimal decrease in the likelihood of disease
0.2 – 0.5 | Small decrease in the likelihood of disease
0.1 – 0.2 | Moderate decrease in the likelihood of disease
< 0.1 | Large and often conclusive decrease in the likelihood of disease

### Algorithms of meta-analysis11

Pooled estimate as a weighted average:

θ_I V_ = (∑_i_ w_i_ θ_i_)/(∑_i_ w_i_)

Weights are inverse of variance (standard error):

w_i_ = (1)/(S E ( θ_i_ )^2^)

Standard error of pooled estimate:

S E ( θ_I V_ ) = (1)/(sqrt(∑_i_ w_i_))

Heterogeneity (between-study variability) measured by:

Q = ∑_i_ w_i_ ( θ_i_ - θ_I V_ )^2^

Assumptions for random effects model: true effect sizes qi have a normal distribution with mean q and variance t2; t2 is the between-study variance

Between study variance:

τ^2^ = (Q - ( k - 1 ))/(∑_i_ w_i_ - ( (∑_i_ w_i_^2^)/(∑_i_ w_i_) ))

Where:

wi are the weights from the fixed effect inverse-variance method

Q is the heterogeneity test statistic from before (either from inverse-variance method or Mantel-Haenszel method)

k is the number of studies, and

t2 is set to zero if Q<k−1

Random effect pooled estimate is weighted average:

θ_D L_ = (∑_i_ w^′^_i_ θ_i_)/(∑_i_ w^′^_i_)

Weights used for the pooled estimate are similar to the inverse-variance, but now incorporate a component for between-study variation:

w^′^_i_ = (1)/(S E ( θ_i_ )^2^ + τ^2^)

Standard error of pooled estimate

S E ( θ_D L_ ) = (1)/(sqrt(∑_i_ w^′^_i_))

Meta regression with random effects was obtained using aggregate level data.

Additive component of variance tau2 was estimated:

y[i] = a + B^*^x[i] + u[i] + e[i],

where u[i] is a normal error (standard deviations that may vary across units), e[i] is a normal error with variance tau2 to be estimated, assumed equal across units.

t-distribution was used calculating p-values and confidence intervals12,13

Attributable risk was calculated as the outcome events rate in patients exposed to different clinical interventions14–16

Attributable risk of the outcome = rate of events in patients in the control group x (relative risk−1)

Number needed to treat to prevent one event of incontinence was calculated as reciprocal to absolute risk differences in rates of outcomes events in the active and control groups:15,17

1/(control group event rate - treatment group event rate).

The number of avoided or excess events (respectively) per 1000 population is the difference between the two event rates multiplied by 1000:

(control group event rate - treatment group event rate)*1000

## References for Appendix D

1 Abrams P. Incontinence: 4th International Consultation on Incontinence. Paris. July 5–8, 2008. 4th ed. [Paris]. Health Publications Ltd. 2009. Committee 1 Epidemiology of Urinary (UI) and Fecal (FI) Incontinence and Pelvic Organ Prolapse (POP).
2 Abrams P, Cardozo L, Fall M, et al. for the Standardisation Sub-Committee of the International Continence Society. The standardisation of terminology in lower urinary tract function: report from the standardisation sub-committee of the International Continence Society. Urology. 2003;61:37-49. [pmid: 12559262].
3 Schorge JO, Schaffer JI, Halvorson LM, et al. Chapter 23. Urinary Incontinence. Schorge JO, Schaffer JI, Halvorson LM, et al., editors. Gynecology. http://www.accessmedicine.com/content.aspx?alD=3150435.
4 Tarnay CM, Bhatia Narender N. Chapter 45. Urinary Incontinence. DeCherney AH, Nathan L, editors. Current Diagnosis & Treatment Obstetrics & Gynecology. 10e. http://www.accessmedicine.com/content.aspx?aID=2390665.
5 Haylen BT, de Ridder D, Freeman RM, et al. An International Urogynecological Association (IUGA)/International Continence Society (ICS) joint report on the terminology for female pelvic floor dysfunction. Neurourol Urodyn. 2010;29(1):4-20. [pmid: 19941278].
6 AHCPR Urinary Incontinence in Adults Guideline Update Panel. Managing acute and chronic urinary incontinence. Am Fam Physician. 1996;54:1661-72. [pmid: 8857788].
7 Resnick NM. Urinary incontinence. Beers MH, Jones TV, Berkwits M, et al., editors. The Merck manual of geriatrics [online]. Whitehouse Station, NJ. Merck & Co. Inc. 2010. Available at http://www.merck.com/mkgr/mmg/home.jsp.
8 Sandvik H, Hunskaar S, Seim A, et al. Validation of a severity index in female urinary incontinence and its implementation in an epidemiological survey. J Epidemiol Community Health. Dec. 1993;47(6):497-9. [pmid: 8120507].
9 U.S. Department of Health and Human Services, Food and Drug Administration, Center for Devices and Radiological Health, et al. Draft Guidance for Industry and FDA Staff - Clinical Investigations of Devices Indicated for the Treatment of Urinary Incontinence. Food and Drug Administration. 5630 Fishers Lane, Room 1061. Available at: http://www.fda.gov/MedicalDevices/DeviceRegulationandGuidance/GuidanceDocuments/ucm070852.htm. Accessed August, 2009. 2009.
10 Altman DG, Bland JM. Diagnostic tests 2: Predictive values. BMJ. Jul. 9. 1994;309(6947):102. [pmid: 8038641].
11 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. Sep. 1986;7(3):177-88. [pmid: 3802833].
12 Knapp G, Biggerstaff BJ, Hartung J. Assessing the amount of heterogeneity in random-effects meta-analysis. Biom J. Apr. 2006;48(2):271-85. [pmid: 16708778].
13 Knapp G, Hartung J. Improved tests for a random effects meta-regression with a single covariate. Stat Med. Sep. 15. 2003;22(17):2693-710. [pmid: 12939780].
14 Kahn HA, Sempos CT. Statistical Methods in Epidemiology (Monographs in Epidemiology and Biostatistics). USA. Oxford University Press. 1989.
15 Egger M, Smith GD, Altman DG. Systematic Reviews in Health Care. London. NetLibrary, Inc BMJ Books. 2001.
16 Dawson B, Trapp RG. Basic & Clinical Biostatistics (LANGE Basic Science). 3rd ed. New York. Lange Medical Books-McGraw-Hill. 2004.
17 Ebrahim S. The use of numbers needed to treat derived from systematic reviews and meta-analysis. Caveats and pitfalls. Eval Health Prof. Jun. 2001;24(2):152-64. [pmid: 11523384].
18 Abrams P. Incontinence: 4th International Consultation on Incontinence. Paris. July 5–8. 2008. 4th ed. [Paris]. Health Publications Ltd. 2009.