# Analysis of Results From Ongoing Studies

Appendix Table C1 Distribution of studies of nonsurgical treatments for UI closed in www.clinicaltrials.gov on May 20, 2010

Categories | Type | Frequency | Percent
Gender | Both | 95 | 57.23
| Female | 71 | 42.77
Age Groups | Adult | 15 | 9.04
| Adult \|Senior | 147 | 88.55
| Child \|Adult \|Senior | 4 | 2.41
Diagnosis | Incontinence | 3 | 1.81
| Overactive Bladder | 96 | 57.83
| Stress Urinary Incontinence | 13 | 7.83
| Urge Incontinence | 4 | 2.41
| Urinary Incontinence | 50 | 30.12
Funding Sources | Industry | 122 | 73.49
| NIH | 5 | 3.01
| NIH/Other | 1 | 0.6
| Other | 23 | 13.86
| Other/Industry | 10 | 6.02
| Other/NIH | 1 | 0.6
| Other/U.S. Fed | 1 | 0.6
| Other\|Unknown/U.S. Fed | 1 | 0.6
| U.S. Fed | 2 | 1.2
Study Types | Interventional | 145 | 87.35
| Observational | 21 | 12.65
Phases of Clinical Trials | Phase I | 9 | 6.57
| Phase II | 32 | 23.36
| Phase III | 59 | 43.07
| Phase II/Phase III | 3 | 2.19
| Phase IV | 32 | 23.36
| Phase I/Phase II | 2 | 1.46
Interventions | Behavioral | 8 | 5.3
| Biological | 4 | 2.65
| Device | 10 | 6.62
| Dietary supplement | 1 | 0.66
| Drug | 121 | 80.13
| Genetic | 1 | 0.66
| Other | 4 | 2.65
| Procedure | 2 | 1.32
Recruitment | Active, not recruiting | 26 | 15.66
| Completed | 120 | 72.29
| Enrolling by invitation | 5 | 3.01
| Terminated | 12 | 7.23
| Withdrawn | 3 | 1.81
Study Results | Has Results | 7 | 4.22
| No Results Available | 159 | 95.78
Publication | No | 138 | 83.13
| Yes | 28 | 16.87

The numbers may not round to the same sum of 166 studies because of missing information.

Appendix Table C2 Posting of results of UI studies by study category in www.clinicaltrial.gov

Categories | Type | Has results | No results available | Total | % with results
Gender | Both | 7 | 88 | 95 | 7.4
| Female | 0 | 71 | 71 | 0.0
Age | Adult | 0 | 15 | 15 | 0.0
| Adult/Senior | 7 | 140 | 147 | 4.8
| Child/Adult/Senior | 0 | 4 | 4 | 0.0
Diagnosis | Incontinence | 0 | 3 | 3 | 0.0
| Overactive Bladder | 6 | 90 | 96 | 6.3
| Stress Urinary Incontinence | 0 | 13 | 13 | 0.0
| Urge Incontinence | 0 | 4 | 4 | 0.0
| Urinary Incontinence | 1 | 49 | 50 | 2.0
Sponsorship | Industry | 6 | 116 | 122 | 4.9
| NIH | 0 | 5 | 5 | 0.0
| NIH/Other | 0 | 1 | 1 | 0.0
| Other | 0 | 23 | 23 | 0.0
| Other/Industry | 0 | 10 | 10 | 0.0
| Other/NIH | 1 | 0 | 1 | 100.0
| Other/U.S. Fed | 0 | 1 | 1 | 0.0
| Other/Unknown/U.S. Fed | 0 | 1 | 1 | 0.0
| U.S. Fed | 0 | 2 | 2 | 0.0
Study Type | Interventional | 7 | 138 | 145 | 4.8
| Observational | 0 | 21 | 21 | 0.0
Phase of Clinical Trials | Phase I | 0 | 9 | 9 | 0.0
| Phase I/Phase II | 0 | 2 | 2 | 0.0
| Phase II | 1 | 31 | 32 | 3.1
| Phase II/Phase III | 0 | 3 | 3 | 0.0
| Phase III | 4 | 55 | 59 | 6.8
| Phase IV | 1 | 31 | 32 | 3.1
Intervention | Behavioral | 0 | 8 | 8 | 0.0
| Biological | 1 | 3 | 4 | 25.0
| Device | 0 | 10 | 10 | 0.0
| Dietary Supplement | 0 | 1 | 1 | 0.0
| Drug | 5 | 116 | 121 | 4.1
| Genetic | 0 | 1 | 1 | 0.0
| Other | 1 | 3 | 4 | 25.0
| Procedure | 0 | 2 | 2 | 0.0
Recruitment | Active, not recruiting | 0 | 26 | 26 | 0.0
| Completed | 7 | 113 | 120 | 5.8
| Enrolling by invitation | 0 | 5 | 5 | 0.0
| Terminated | 0 | 12 | 12 | 0.0
| Withdrawn | 0 | 3 | 3 | 0.0
Publication | No | 4 | 134 | 138 | 2.9
| Yes | 3 | 25 | 28 | 10.7

Appendix Table C3 Reporting of results by sponsors of closed studies of UI (sorted by total number of funded studies, shown if more than one study was funded)

Sponsors | Has results | No results available | Total | % with results
Total | 7 | 159 | 166 | 4
Pfizer | 3 | 26 | 29 | 10
Astellas Pharma, Inc. | 0 | 14 | 14 | 0
Eli Lilly and Company/Boehringer Ingelheim Pharmaceuticals | 0 | 12 | 12 | 0
GlaxoSmithKline | 0 | 6 | 6 | 0
Allergan | 1 | 3 | 4 | 25
Alza Corporation, DE, USA | 0 | 4 | 4 | 0
Eli Lilly and Company | 0 | 4 | 4 | 0
Duramed Research | 0 | 3 | 3 | 0
Merck | 0 | 3 | 3 | 0
Novartis/Procter and Gamble | 0 | 3 | 3 | 0
Ono Pharma | 0 | 3 | 3 | 0
Uroplasty, Inc | 0 | 3 | 3 | 0
Astellas Pharma Inc./Astellas Pharma Europe BV | 0 | 2 | 2 | 0
Astellas Pharma Inc./Astellas Pharma Korea, Inc. | 0 | 2 | 2 | 0
Bayer | 0 | 2 | 2 | 0
Cleveland Clinic Florida/Astellas Pharma US, Inc. | 0 | 2 | 2 | 0
Department of Veterans Affairs | 0 | 2 | 2 | 0
Eunice Kennedy Shriver National Institute of Child Health and Human Development (NICHD) | 0 | 2 | 2 | 0
Kissei Pharmaceutical Co., Ltd. | 0 | 2 | 2 | 0
Medtronic Neuro | 0 | 2 | 2 | 0
Novartis | 0 | 2 | 2 | 0
Sanofi-Aventis | 0 | 2 | 2 | 0
University of Michigan | 0 | 2 | 2 | 0
William Beaumont Hospitals | 0 | 2 | 2 | 0
Watson Pharmaceuticals | 1 | 1 | 2 | 50

Appendix Table C4 Publication of results in peer reviewed journals by categories of studies of UI

Category | Type | Not Published in peer reviewed journals | Published in peer review journals | Total | % published
Gender | Both | 80 | 15 | 95 | 16
| Female | 58 | 13 | 71 | 18
Age | Adult | 14 | 1 | 15 | 7
| Adult/Senior | 121 | 26 | 147 | 18
| Child/Adult/Senior | 3 | 1 | 4 | 25
Diagnosis | Incontinence | 3 | 0 | 3 | 0
| Overactive Bladder | 80 | 16 | 96 | 17
| Stress Urinary Incontinence | 12 | 1 | 13 | 8
| Urge Incontinence | 4 | 0 | 4 | 0
| Urinary Incontinence | 39 | 11 | 50 | 22
Sponsorship | Industry | 105 | 17 | 122 | 14
| NIH | 1 | 4 | 5 | 80
| NIH/Other | 1 | 0 | 1 | 0
| Other | 18 | 5 | 23 | 22
| Other/Industry | 9 | 1 | 10 | 10
| Other/NIH | 1 | 0 | 1 | 0
| Other/U.S. Fed | 1 | 0 | 1 | 0
| Other/Unknown/U.S. Fed | 1 | 0 | 1 | 0
| U.S. Fed | 1 | 1 | 2 | 50
Study Type | Interventional | 119 | 26 | 145 | 18
| Observational | 19 | 2 | 21 | 10
Phase of Clinical Trials | Phase I | 9 | 0 | 9 | 0
| Phase I \|Phase II | 2 | 0 | 2 | 0
| Phase II | 30 | 2 | 32 | 6
| Phase II\| Phase III | 1 | 2 | 3 | 67
| Phase III | 45 | 14 | 59 | 24
| Phase IV | 25 | 7 | 32 | 22
Intervention | Behavioral | 4 | 4 | 8 | 50
| Biological | 4 | 0 | 4 | 0
| Device | 10 | 0 | 10 | 0
| Dietary Supplement | 1 | 0 | 1 | 0
| Drug | 99 | 22 | 121 | 18
| Genetic | 1 | 0 | 1 | 0
| Other | 4 | 0 | 4 | 0
| Procedure | 2 | 0 | 2 | 0
Recruitment | Active, not recruiting | 24 | 2 | 26 | 8
| Completed | 95 | 25 | 120 | 21
| Enrolling by invitation | 5 | 0 | 5 | 0
| Terminated | 12 | 0 | 12 | 0
| Withdrawn | 2 | 1 | 3 | 33

Appendix Table C5 Publication of results in peer reviewed journals by sponsors of studies of UI (sorted by total number of sponsored studies; shown if more than one study was sponsored)

Sponsors | Not published in peer review journals | Published in peer review journals | Total | % published
| No | Yes
Total | 138 | 28 | 166 | 17
Pfizer | 25 | 4 | 29 | 14
Astellas Pharma, Inc. | 10 | 4 | 14 | 29
Eli Lilly and Company/Boehringer Ingelheim Pharmaceuticals | 11 | 1 | 12 | 8
GlaxoSmithKline | 6 | 0 | 6 | 0
Allergan | 4 | 0 | 4 | 0
Alza Corporation, DE, USA | 3 | 1 | 4 | 25
Eli Lilly and Company | 3 | 1 | 4 | 25
Duramed Research | 3 | 0 | 3 | 0
Merck | 3 | 0 | 3 | 0
Novartis/Procter and Gamble | 2 | 1 | 3 | 33
Ono Pharma | 3 | 0 | 3 | 0
Uroplasty, Inc. | 3 | 0 | 3 | 0
Astellas Pharma Inc./Astellas Pharma Europe BV | 2 | 0 | 2 | 0
Astellas Pharma Inc./Astellas Pharma Korea, Inc. | 1 | 1 | 2 | 50
Bayer | 2 | 0 | 2 | 0
Cleveland Clinic Florida/Astellas Pharma US, Inc. | 1 | 1 | 2 | 50
Department of Veterans Affairs | 1 | 1 | 2 | 50
Eunice Kennedy Shriver National Institute of Child Health and Human Development (NICHD) | 0 | 2 | 2 | 100
Kissei Pharmaceutical Co., Ltd. | 2 | 0 | 2 | 0
MedtronicNeuro | 2 | 0 | 2 | 0
Novartis | 1 | 1 | 2 | 50
Sanofi-Aventis | 2 | 0 | 2 | 0
University of Michigan | 0 | 2 | 2 | 100
Watson Pharmaceuticals | 0 | 2 | 2 | 100
William Beaumont Hospitals | 2 | 0 | 2 | 0