# Excluded Studies

(Note that this set of references is different from those in the text, and the numbers are different.)

(Reason for exclusion shown in italics at the end of each reference.)

1 Evaluation and treatment of urinary incontinence. Urologic Clinics of North America. 1991;18(2):175-407. Level of evidence.
2 Safety in the therapy of urinary incontinence. A workshop on the occasion of the 22nd Congress of the International Urology Society, Seville, 4 November 1991. Sicherheitin der Harninkontinenz-Therapie. Workshop anlässlich des 22. Kongresses der Societé International d’Urologie. Sevilla. 4, November 1991. 1992;31(2 Suppl):1-12. Level of evidence.
3 Safety in the therapy of urinary incontinence. II. Specialty workshop, 22nd Congress of the International Society of Urology, Seville, 4 November 1991. Sicherheit in der Harninkontinenz-therapie. II. Fachpresse-workshop, 22. Kongresses der Societé International d’Urologie. Sevilla. 4 November 1991. 1992;25(1 Suppl):1-12. Level of evidence.
4 Stress urinary incontinence in clinical practice. Advanced Studies in Medicine. 2003;3(8 E). Level of evidence.
5 Successful treatment possibilities for urinary incontinence. The 2nd Urogynecology Congress in St. Veita.d. Glan. Erfolgreiche behandlungs-möglichkeiten bei harninkontinenz. 2. Urogynäkologie-Kongress in St. Veit a.d. Glan. 2004;11(2):43. Level of evidence.
6 Advancing the treatment of fecal and urinary incontinence through research: trial design, outcome measures, and research priorities. Proceedings of a consensus conference. November 3–5, 2002. Milwaukee, Wisconsin, USA. Gastroenterology. 2004;126(1 Suppl 1). Level of evidence.
7 Aaronson PS, Loehner D, Bingham W, et al. Intravaginal electrical stimulation in the treatment of genuine stress urinary incontinence and detrusor instability: A controlled study. Paper presented at: American Urological Society 90th Annual Meeting. Las Vegas, NV (USA). 23–28 April 1995. (World Meeting Number 952 0772). Level of evidence.
8 Abdelbary A. Evaluation of prolene mesh as a trans-obturator tape for treatment of female stress urinary incontinence. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
9 Abdel-Karim AM, Hassouna ME, Koraitem MA, et al. Vaginal Inter-Pubic Perineorraphy for Treatment of Female Stress Urinary Incontinence: A New Technique. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
10 Abramov Y, Rosen T, Feiner B, et al. Does a &#39;One Stop&#39; Urogynecologic Clinic Improve Patients&#39; Compliance for Behavioral Therapy for Urinary Incontinence?. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
11 Accorsi-Neto AC. Long-term evaluation of patients with Kelly Kennedy surgery for urinary incontinence treatment. Paper presented at: XVII FIGO World Congress of Gynecology and Obstetrics. Santiago (Chile). 2–7 Nov 2003. (World Meeting Number 000 7240). Level of evidence.
12 ACTRN12605000755639. Efficacy of non-invasive magnetic stimulation of the pelvic floor in the control of urinary incontinence. Not eligible exposure.
13 Adamiak A, Jankiewicz K, Miotla P, et al. Efficacy and safety of transobturator approach in the treatment of female stress urinary incontinence. Paper presented at: 12th World Congress on Human Reproduction. Venice (Italy). 10–13 Mar 2005. (World Meeting Number 000 0000). Level of evidence.
14 Adile B. New treatment for stress urinary incontinence. Paper presented at: XVII FIGO World Congress of Gynecology and Obstetrics. Santiago (Chile). 2–7 Nov 2003. (World Meeting Number 000 7240). Level of evidence.
15 Adile B, Gugliotta G, Adile G. A two-year follow-up of a new readjustable transobturator approach for surgical treatment of female stress urinary incontinence. Urogynaecologia International Journal. 2006;20(2):307-9. Level of evidence.
16 Adile B, Liguori P, Pisapia G, et al. Tension-free vaginal tape for surgical treatment of stress urinary incontinence. An Italian multicenter study and two year follow-up. TVT per il trattamento chirurgico della incontinenza urinaria da sforzo. Studio multicentrico italiano. Follow-up a due anni. 2001;15(1 SUPPL):68. Level of evidence.
17 Adile B, Palma P, Thiel R, et al. Female sexual function before and after treatment of urinary incontinence. Urogynaecologia International Journal. 2005;19(1 SUPPL):365-72. Level of evidence.
18 Adile BA, Gugliotta GG, Adile GA. A Two-Year Follow-Up of a New Readjustable Transobturator Approach for Surgical Treatment of Female Stress Urinary Incontinence. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
19 Aguirre OA. Acute Pudendal Nerve Stimulation Improves Cystometric Volumes in Urge Incontinent Patients. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
20 Agur W, Steggles P, Waterfield M, et al. Is Antenatal Pelvic Floor Muscle Training Still Effective after Eight Years?. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
21 Al-Hazmi HH. Endoscopic Polydimethylsiloxane Treatment of Intractable Sphincteric Urinary Incontinence. Paper presented at: 18th Annual Saudi Urological Conference. Jeddah (Saudi Arabia). 20–23 Feb 2006. Level of evidence.
22 Alio L, Accursio MC, Incandela S, et al. Pelvic perineal kinesitherapy combined with functional electric stimulation in the treatment of urinary incontinence in women. Elettrostimolazione funzionale associata alla chinesi terapia pelvi-perineale nel trattamento conservativo della I.U. femminile. 2001;15(1 SUPPL):46-7. Level of evidence.
23 Almeida SHM, Gregório E, Grando JPS, et al. Pubovaginal sling using cadaveric allograft fascia for the treatment of female urinary incontinence. Transplantation Proceedings. 2004;36(4):995-6. Level of evidence. [pmid: 15194346].
24 Amarenco G. On the subject of the ANAES Recommendations for good practice: Management of female urinary incontinence in general medicine (May 2003). À propos des RPC de l’ANAES: Prise en en charge de l’incontinence urinaire de la femme en ḿdecine ǵ ńrale (mai 2003). 2004;32(12):1082. Level of evidence.
25 Amaro JL, Jesus CMN, Yamamoto H, et al. A New Surgical Approach to Treatment of Urethral Stenosis Associated with Stress Urinary Incontinence in Woman. Paper presented at: 2008 Annual Meeting of the American Urological Association. Orlando, Florida (USA). 17–22 May 2008. Level of evidence.
26 Amaro JL, Yamamoto HA, Kawano PR, et al. A Prospective Randomized Trial of Autologous Fascial Sling (AFS) Versus Tension-Free Vaginal Tape (TVT) for Treatment of Stress Urinary Incontinence (SUI). Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Level of evidence.
27 Amaye-Obu FA, Drutz HP. Surgical management of recurrent stress urinary incontinence: A 12-year experience. American Journal of Obstetrics and Gynecology. 1999;181(6):1296-309. Level of evidence. [pmid: 10601904].
28 Amicarelli F, Bougnaguidi A, Pifarotti P, et al. Combined treatment of anterior vaginal prolapse associated with stress urinary incontinence using tension-free vaginal tape and endopelvic tascia plication. Trattamento combinato del prolasso vaginale anteriore associato ad incontinenza utinaria da sforza mediante tension-free vaginal tape e duplicatura dell fascia pubovescicocervicale. 2001;15(1 SUPPL):51-4. Level of evidence.
29 Anaf V, Simon P, Buxant F. Treatment of stress urinary incontinence in women and the place of physiotherapy. Le traitement de l’incontinence urinaire chez la femme et la place de la kinésithérapie. 2003;24:4. Level of evidence.
30 Andersson KE. Muscarinic receptor antagonists in the treatment of urinary incontinence - Clinical experience. Paper presented at: The 9th Symposium on Subtypes of Muscarinic Receptors. Houston, Texas (USA). 31 Oct–4 Nov 2000. (World Meeting Number 000 5147). Level of evidence.
31 Andres M. Treatment of prolapse of pelvic organ by collocation of total mesh and collocation of suburetral mesh for the urinary incontinence of effort in corpse with later dissection. Paper presented at: 18th Annual Congress of the European Society for Gynaecological Endoscopy (ESGE 2009), Palazzo dei Congressi. Florence. 28–31 Oct 2009. Level of evidence.
32 Arnold S, Hubler M, Reichler I. Urinary incontinence in spayed bitches: New insights into the pathophysiology and options for medical treatment. Reproduction in Domestic Animals. 2009;44(SUPPL 2):190-2. Level of evidence. [pmid: 19754565].
33 Arslan M, Degirmenci T, Gunlusoy B, et al. Outcomes of Transobturator Vaginal Tape Procedure with Polypropylene Mesh in the Treatment of Stress Urinary Incontinence: Cheap and Effective. Paper presented at: 26th World Congress of Endourology (WCE 26), Shanghai International Convention Center (SICC). Shanghai (China). 30 Nov–3 Dec 2008. Level of evidence.
34 Arvis G, Chamlou F, Sellam R. Treatment of urinary incontinence by subcervical infection of teflon. Paper presented at: AUA 1986 Eighty-First Annual Meeting. New York, NY (USA). 18–22 Mar 1986. (World Meeting Number 862 0424). Level of evidence.
35 Austoni E, Ceresoli A, Guarneri A, et al. The sling tension-free to a different component in the mini-invasive treatment of stress urinary incontinence from urethral hypermobility: Materials, methods and results. Lo sling tension free a componente differenziata nel trattamento mininvasivo della incontinenza urinaria da ipermobilità uretrale: Materiali, metodi e risultati. 2005;19(1 SUPPL):162-4. Level of evidence.
36 Avgerinos AA, Koufomichail VK, Arkomani BA, et al. Tvt or Tvt-Obturator? Our Experience in using Both Methods for Treatment of Stress Urinary Incontinence. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
37 Awad SA, Gajewski JB, Bourque-Kehoe A. Stress urinary incontinence and its treatment in women over sixty. Paper presented at: 53rd Annual Meeting of the Canadian Urological Association (CUA). Halifax, Nova Scotia (Canada). 21–25 Jun 1998. (World Meeting Number 982 5037). Level of evidence.
38 Axelsson E. Prevalence of urinary incontinence in women with obstructive lung disease. Paper presented at: 12th International Congress of the World Federation for Physical Therapy. Washington DC (USA). 25–30 Jun 1996. (World Meeting Number 962 5007). Level of evidence.
39 Badlani G Penile prosthesis in the treatment of urinary incontinence Paper presented at: AUA 1986 Eighty-First Annual Meeting New York, NY (USA) 18–22 Mar 1986 (World Meeting Number 862 0424)sLevel of evidence
40 Bae JH, Kim JW, Cheon J, et al. Comparative Study of Modified Transobturator Tape (M-TOT) and Conventional Tot: A Novel Approach in Surgical Treatment for Stress Urinary Incontinence (SUI). Paper presented at: 2006 Annual Meeting of the American Urological Association (AUA 2006). Atlanta, Georgia (USA). 20–25 May 2006. Level of evidence.
41 Balakrishnan S, Arumainathan T, Rahman A. Comparative Study of Desara Sling System vs Monarc Subfascial Hammock for Treatment of Stress Urinary Incontinence- a Medium Term Review in Penang Hospital. Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Level of evidence.
42 Balmforth J, Cardozo LD. Trends toward less invasive treatment of female stress urinary incontinence. Urology. 2003;62(4 SUPPL 1):52-60. Level of evidence. [pmid: 14550838].
43 Baranowski W, Doniec J, Baczkowski M, et al. Surgical Treatment of Female Stress Urinary Incontinence with Gynecare TVT Secur(TM) System - Preliminary Report. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
44 Bartsch G Sr, Dalpiaz O, Kerschbaumer A, et al. Transobturator Male Artificial Slings in Treatment of Male Urinary Incontinence: Late Results and Complications. Paper presented at: 2008 Annual Meeting of the American Urological Association. Orlando, Florida (USA). 17–22 May 2008. Level of evidence.
45 Bautista Gomez E, Gonzalez Gonzalez E, Rodriguez Colorado S, et al. Transobturator Tape for the Treatment of Stress Urinary Incontinence: The National Institute of Perinatology Experience in Mexico. Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Level of evidence.
46 Baya G, Janin P. A Single Incision Tot: 2 Years Follow up Experience for the Surgical Treatment of Stess Urinary Incontinence. Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Level of evidence.
47 Baya G, Janin P, Navazo R. Surgical Procedure with Local Anesthesia for the Treatment of Stress Urinary Incontinence: A Single Incision Tot. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
48 Baya G, Janin P, Navazo R. Multicenter Study for the Surgical Treatment of Stress Urinary Incontinence in Women with a Single Incision Tot Technique. Two Years Follow Up. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
49 Beck C, O’Donnell PD. Biofeedback therapy of urinary incontinence (UI) in elderly inpatient men. Paper presented at: American Public Health Association 116th Annual Meeting. Boston, MA (USA). 13–17 Nov 1988. (World Meeting Number 884 0704). Level of evidence.
50 Bekedam DM, Sluijs EM. Effects of exercises on urinary incontinence. Paper presented at: 12th International Congress of the World Confederation for Physical Therapists. Washington DC (USA). 20–25 Jun 1995. (World Meeting Number 952 0043). Level of evidence.
51 Benassi L, Marconi L, Benassi G, et al. Treatment of stress urinary incontinence through TOT: Our experience. Trattamento dell’incontinenza urinaria da sforzo mediante TOT: La nostra esperienza. 2005;19(1 SUPPL):144-5. Level of evidence.
52 Ben-Chaim J, Jeffs RD, Peppas DS, et al. Submucosal bladder neck injections of glutaraldehyde cross-linked bovine collagen for the treatment of urinary incontinence in patients with the exstrophy/epispadias complex. Journal of Urology. 1995;154(2 II SUPPL):862-4. Level of evidence. [pmid: 7609199].
53 Berghmans L, Hendriks H, Bo K, et al. Conservative treatment of stress urinary incontinence in woman. A systematic review of randomized clinical trials. Paper presented at: 27th Annual Meeting of the International Continence Society. Yokohama (Japan). 23–26 Sep 1997. (World Meeting Number 973 0118). Level of evidence.
54 Berkers J, Van Der Aa F, De Ridder D, et al. The Minimal Invasive Miniarc Sling versus Monarc Trans-Obturator Sling System in the Treatment of Female Stress Urinary Incontinence. Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Level of evidence.
55 Bhakta T. The Development of Stem Cell Therapy for Stress Urinary Incontinence. Paper presented at: 31st British International Congress of Obstetrics and Gynaecology (BICOG 2007). ExCeL, London (UK). 4–6 Jul 2007. Level of evidence.
56 Bidmead J. Urinary Incontinence: A Gynaecologist’s Experience. European Urology Supplements. 2002;1(10):21-4. Level of evidence.
57 Biller DH, Guerette NL, Jean-Michel M, et al. Are Retropubic Slings More Effective than Transobturator Slings for the Surgical Treatment of Severe Stress Urinary Incontinence?. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
58 Bladou F, Rossi D, Serment G, et al. Medical treatment of urinary incontinence due to bladder instability. LE TRAITEMENT MEDICAL DES INCONTINENCES URINAIRES PAR ‘INSTABILITE VESICALE’. 1993;88(3):129-31. Level of evidence.
59 Blaivas JG. Urinary incontinence after radical prostatectomy. Cancer. 1995;75(7 SUPPL):1978-82. Level of evidence.
60 Blok BFM, Corcos J. Surgery for stress urinary incontinence in women: A 2006 review. Indian Journal of Urology. 2007;23(2):148-52. Level of evidence. [pmid: 19675792].
61 Bo K. Long-term effect of pelvic floor muscle exercise to treat female stress urinary incontinence. Paper presented at: 12th International Congress of the World Federation for Physical Therapy. Washington DC (USA). 25–30 Jun 1996. (World Meeting Number 962 5007). Level of evidence.
62 Boerma MO, auwers K, Heesakkers JPFA. Results of Bioslings and Causes of Failure after Surgery for Complex Stress Urinary Incontinence. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Level of evidence.
63 Bölükbaş N, Vural M, Karan A, et al. Effectiveness of functional magnetic versus electrical stimulation in women with urinary incontinence. Europa Medicophysica. 2005;41(4):297-301. Level of evidence. [pmid: 16474284].
64 Borello-France D, Zyczynski H, Gruss J, et al. Development and psychometric testing of expectation/satisfaction questionnaires specific to urinary incontinence surgery. Paper presented at: 23rd Annual Meeting of the American Urogynecologic Society. San Fracisco, CA (USA). 17–19 Oct 2002. (World Meeting Number 000 6467). Level of evidence.
65 Bortolini M, Miranda V, Ahmed R, et al. Transobturator Tape for the Treatment of Stress Urinary Incontinence: Effectiveness and Predictors of Outcome. Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Level of evidence.
66 Botros SM, Miller JJR, Goldberg RP, et al. Detrusor overactivity and urge urinary incontinence following trans obturator versus midurethral slings. Neurourology and Urodynamics. 2007;26(1):42-5. Level of evidence. [pmid: 17149712].
67 Bourcier A. Conservative treatment of the female urinary incontinence. Traitement conservateur de l’incontinence urinaire féminine. 2006;1(SUPPL 1). Level of evidence.
68 Bouzouita A, Sfaxi M, Cherif M, et al. Stress Urinary Incontinence Treatment Using Synthetic Tape. About 60 Cases. Paper presented at: 21st Annual Congress of the European Association of Urology (EAU 2006), Palais des Congres. Paris (France). 5–8 Apr 2006. Level of evidence.
69 Brandner P, Dietz HP, Impfling M, et al. Perineal sonography in the diagnosis of recurrence after surgery for urinary incontinence. DAS PLASTISCHE REZIDIV NACH INKONTINENZOPERATIONEN: EINE PERINEALSONOGRAPHISCHE LONGITUDINALSTUDIE. 1991;250(1–4):337-8. Level of evidence.
70 Brands FH, Schewe J, Pannek J. Urinary incontinence. The 23rd Bochum therapy meeting. May 27, 2000. Harninkontinenz. 23. Bochumer therapietag, 27. Mai 2000. 2000;40(5):459-60. Level of evidence.
71 Bratila CP. Subutheral Prosthetic Support in the Treatment of Current Stress Urinary Incontinence Free or Low Tension. Paper presented at: XVIII FIGO World Congress of Gynecology and Obstetrics (FIGO 2006). Kuala Lumpur Convention Centre (KLCC), Kuala Lumpur (Malaysia). 5–10 Nov 2006. Level of evidence.
72 Breda G, Tamai A. Ambulatory surgical treatment in urinary stress incontinence in women. IL TRATTAMENTO CHIRURGICO AMBULATORIALE DELL’INCONTINENZA URINARIA DA SFORZO NELLA DONNA. 1993;7(SUPPL 1):75-6. Level of evidence.
73 Breen JM, Geer BE, May GE, et al. The fascia lata suburethral sling for treating recurrent urinary stress incontinence. American Journal of Obstetrics and Gynecology. 1997;177(6):1363-6. Level of evidence. [pmid: 9423736].
74 Brocklehurst JC. Urinary incontinence in old age: Helping the general practitioner to make a diagnosis. Gerontology. 1990;36(SUPPL 2):3-7. Level of evidence. [pmid: 2227474].
75 Brown JS, Nyberg LM, Kusek JW, et al. Proceedings of the National Institute of Diabetes and Digestive and Kidney Diseases International Symposium on epidemiologic issues in urinary incontinence in women. American Journal of Obstetrics and Gynecology. 2003;188(6). Level of evidence.
76 Brubaker L. Surgical Treatment of Urinary Incontinence in Women Gastroenterology. 2004;126(1). Level of evidence.
77 Bumbu G, Maghiar TT, Szilagy L, et al. TVT and TOT in treatment of stress urinary incontinence (Autologous fascia). Urogynaecologia International Journal. 2006;20(2):124-5. Level of evidence.
78 Bump RC, Bent AE, Gousse AE, et al. Duloxetine Treatment of Women with Mixed Urinary Incontinence (MUI). Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
79 Bump RC, Castro Diaz D, Palma P, et al. Effect of Dose Escalation on Duloxetine Tolerability and Efficacy in Stress Urinary Incontinence (SUI). Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
80 Buonaguidi A, Pifarotti P, Gattei U, et al. Study on the efficacy of Tension-Free Vaginal Tape in the treatment of stress urinary incontinence with low-pressure urethra. Studio sull’efficacia del Tension Free Vaginal Tape (TVT) nel trattamento dell’incontinenza urinaria da sforzo con bassa pressione di chiusura uretrale. 2001;15(1 SUPPL):61-5. Level of evidence.
81 But I. Treatment options for female stress urinary incontinence. Gynaecologia et Perinatologia, Supplement. 2004;13(1):74-8. Level of evidence.
82 Butler RN, Maby JI, Montella JM, et al. Urinary incontinence: When to refer for procedural therapies. Geriatrics. 1999;54(12):49-56. Level of evidence. [pmid: 10605435].
83 Cabrera J, Bravo I, Perez G, et al. Trt (Remeex System) for the Surgical Treatment of Stress Urinary Incontinence. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
84 Caione P, Capozza N. Endoscopic treatment of urinary incontinence in pediatric patients: 2-Year experience with dextranomer/hyaluronic acid copolymer. Journal of Urology. 2002;168(4 II):1868-71. Level of evidence. [pmid: 12352378].
85 Campeau L, Tu LM, Lemieux MC, et al. A Multicenter Prospective Randomized Clinical Trial Comparing Tension-Free Vaginal Tape Surgery and No Treatment for the Management of Stress Urinary Incontinence in Elderly Women. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
86 Carbone A, Trucchi A, Petta S, et al. Pubourethral bone anchored sling in the treatment of female stress urinary incontinence: Medium-term results. Sling pubo-uretrale ad ancoraggio osseo nel trattamento dell’incontinenza urinaria da stress femminile: Risultati a medio termine. 2001;15(1 SUPPL):200-1. Level of evidence.
87 Carr LK, Steele D, Steele S, et al. Muscle Derived Cell Injection Technique to Optimze the Treatment of Stress Urinary Incontinence. Paper presented at: 2006 Annual Meeting of the American Urological Association (AUA 2006). Atlanta, Georgia (USA). 20–25 May 2006. Level of evidence.
88 Carr LK, Steele D, Steele S, et al. University of Toronto Clinical Trial of Muscle-Derived Cell Injection in Women with Stress Urinary Incontinence. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Level of evidence.
89 Casanova J, Maciel R, Costa V, et al. Mean Five-Year Follow-up of the Tension-Free Vaginal Tape Procedure for Treatment of Urinary Incontinence. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
90 Castillo M, Casas Balazote A, Muooz Sanchez R, et al. Urinary Incontinence after the Treatment of Gynaecological Oncological Surgery: Our Experience. Paper presented at: 11th World Congress on Controversies in Obstetrics, Gynecology and Infertility (COGI 2008). Paris (France). 27–30 Nov 2008. Level of evidence.
91 Cerruto MA, Cardarelli S, Aloisi A, et al. Pubo-vaginal sling using cadaveric fascia lata in the treatment of female stress urinary incontinence due to a sphincteric deficiency: our experience with a 10-year follow-up. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008). Cairo International Congress Center (CICC), Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
92 Cervigni M, Natale F. Surgical treatment of stress urinary incontinence. European Journal of Obstetrics Gynecology and Reproductive Biology. 1999;85(1):63-70. Level of evidence.
93 Cervigni M, Vittori G, Panei M. The modified Pereyra/Raz procedure in the treatment of urinary stress incontinence: 9-year follow up. L’INTERVENTO DI PEREYRA/RAZ MODIFICATO NEL TRATTAMENTO DELL’INCONTINENZA URINARIA DA SFORZO: FOLLOW-UP A 9 ANNI. 1992;6(SUPPL 4):245-6. Level of evidence.
94 Chapple C. The Diagnosis of Urinary Incontinence: Urodynamics, More or Less?. European Urology, Supplements. 2002;1(10):25-8. Level of evidence.
95 Chung MK, Chung RP. Comparison of laparoscopic burch and TVT procedures for treatment of stress urinary incontinence in obese women after 24 to 36 months of follow-up. Paper presented at: 31st Annual Meeting of the International Congress of Gynecologic Endoscopy. Miami Beach, FL (USA). 20–24 Nov 2002. (World Meeting Number 000 6527). Level of evidence.
96 Chutka DS, Fleming KC, Evans MP, et al. Urinary incontinence in the elderly population. Mayo Clinic Proceedings. 1996;71(1):93-101. Level of evidence. [pmid: 8538240].
97 Cioffi GP, Budetta C, Guarino G. Tension-Free Vaginal Tape for the treatment of stress urinary incontinence in women: Own experience. TVt (Tension Free Vaginal Tape) per il trattamento della incontinenza urinaria da sforzo femminile. Nostra esperienza. 2001;15(1 SUPPL):210-2. Level of evidence.
98 Clark A, Romm J. Effect of urinary incontinence on sexual activity in women. Journal of Reproductive Medicine for the Obstetrician and Gynecologist. 1993;38(9):679-83. Level of evidence. [pmid: 8254588].
99 Coco A, Mattei FM, Pitzalis M, et al. Duloxetine in the treatment of stress urinary incontinence. La Doluxetina nel trattamento dell’incontinenza urinaria da stress. 2005;19(1 SUPPL):258-9. Level of evidence.
100 Coleman KW, Millar AL, Bermeo L, et al. Comparison of Expiratory Carbon Dioxide Levels in Women with and without Urinary Incontinence. Paper presented at: 2008 Annual Conference and Exposition of the American Physical Therapy Association (PT 2008). San Antonio, Texas (USA). 11–14 Jun 2008. Level of evidence.
101 Colvert JR Iii, Kropp BP, Cheng EY, et al. The use of small intestinal submucosa as an off-the-shelf urethral sling material for pediatric urinary incontinence. Journal of Urology. 2002;168(4 II):1872-6. Level of evidence. [pmid: 12352379].
102 Coscione M, Costa A, Angelozzi G, et al. Combination of TVT and vaginal wall sling in the treatment of recurrent stress urinary incontinence post TVT. Combinazione di TVT e Wall Vaginal Sling nel trattamento della incontinenza urinaria da sforzo recidiva post TVT. 2005;19(1 SUPPL):146-7. Level of evidence.
103 CTRI/2009/091/000820. A comparative, single blind, parallel group, non-crossover, multi-centric trial of Imidafenacin Tablets 0.1 mg, with Uritos Tablets, in-patients suffering from Overactive Bladder. Not eligible exposure.
104 Cucinella G, Adile B, Gugliotta G, et al. Burch laparoscopy for the treatment of stress urinary incontinence: Long-term follow-up. Burch laparoscopica per il trattamento della incontinenza urinaria da sforzo follow-up a lungo termine. 2001;15(1 SUPPL):117-8. Level of evidence.
105 Cundiff GW. New horizons in stress urinary incontinence treatment. Advanced Studies in Medicine. 2004;4(3 C). Level of evidence.
106 Das S. Dynamic suburethral suspension with pedicled external oblique aponeurosis in the management of female urinary incontinence. Journal of Urology. 1999;162(2):469-73. Level of evidence. [pmid: 10411059].
107 Dave DS, Gunther-Lopez V, Zhang R, et al. Periurethral Injection of Autologous Adipose-Derived Stem Cells with Hepatocyte Growth Factor-Impregnated PLGA Microspheres for Treatment of Stress Urinary Incontinence in an Animal Model. Paper presented at: 2008 Annual Meeting of the American Urological Association. Orlando, Florida (USA). 17–22 May 2008. Level of evidence.
108 de Jong M, Aalders K, Dijkhuizen P, et al. The effect of transobturator tape for treatment of stress urinary incontinence on female sexual functioning. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
109 de Jong M, Aalders K, Dijkhuizen P, et al. Results of the Uretex TOARG transobturator tape for treatment of stress urinary incontinence in women. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
110 de Leval J, Waltregny D. The Inside-out Transobturator Sling for the Treatment of Male Urinary Incontinence. Paper presented at: 2008 Annual Meeting of the American Urological Association. Orlando, Florida (USA). 17–22 May 2008. Level of evidence.
111 De Matteis G, Colagrande S, Maglioni Q, et al. Tension-free vaginal tape: A new procedure for the treatment of stress urinary incontinence. Own experience. TVT (Tension Free Vaginal Tape): Tecnica innovativa risolutiva della IUS. La nostra esperienza. 2001;15(1 SUPPL):72-3. Level of evidence.
112 De Matteis G, Paesano PG, Castellano F, et al. TVT-S for the treatment of stress urinary incontinence: Follow-up after two years. TVT-S per il trattamento dell’incontinenza urinaria da sforzo: Follow-up a due anni. 2008;22(2):115-9. Level of evidence.
113 del Amo E, Santamaria X, Basil C, et al. Tfs in the treatment of genital prolapse and sui (stress urinary incontinence): one year evaluation. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
114 DeLancey JOL. Stress urinary incontinence: Where are we now, where should we go?. American Journal of Obstetrics and Gynecology. 1996;175(2):311-9. Level of evidence. [pmid: 8765247].
115 Delgado D, Drake M. A Randomised Study to Compare the Pelvictoner Device against Standard Pelvic Floor Exercises in the Treatment of Stress Urinary Incontinence in Women. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
116 Dell, ro A, Braun H, et al. Complications after Tension Free Mid Urethral Sling Procedure for Stress Urinary Incontinence (TVT-TOT): Diagnosis and Management. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
117 Descouvieres C, Riveros L, Cohen D, et al. Surgical Experience with Transobturator Vaginal Tape Inside-Out (TVT-O) for the Treatment of Female Stress Urinary Incontinence. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
118 Deval BD, Ferchaux JF, Rafii AR, et al. Objective and Subjective Cure Rates after Trans-Obturator Tape (OBTAPE RG) Treatment of Female Urinary Incontinence. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
119 Didzun D. Urinary incontinence: Successful treatment possible in 80% of the patients. TW Urologie Nephrologie. 1991;3(2):123-6. Level of evidence.
120 Dietz HP. Classifying Major Delivery-Related Pelvic Floor Trauma. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
121 Dinc A, Beji MK, Yalcin O. Efficiency of Pelvic Floor Muscle Exercises in Treatment and Prevention of Urinary Incontinence during Pregnancy and Postpartum Period. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
122 Djehdian L, De Araujo M, Oliveira M, et al. Surgical Treatment of Female Stress Urinary Incontinence with Ophira Mini Sling System - Preliminary Report. Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Level of evidence.
123 Dodd ME, Langman H. Urinary incontinence in cystic fibrosis. Journal of the Royal Society of Medicine, Supplement. 2005;98(45):28-36. Level of evidence.
124 Downs LS. Urinary Incontinence in Women with Gynecologic Malignancies before and after Primary Therapy. Paper presented at: 43rd Annual Meeting of the American Society of Clinical Oncology. McCormick Place, Chicago, Illinois (USA). 1–5 Jun 2007. Level of evidence.
125 Dylewski DA, Jamison MG, Borawski KM, et al. A Statistical Comparison of Pad Numbers versus Pad Weights in the Quantification of Urinary Incontinence. Paper presented at: 2006 Annual Meeting of the American Urological Association (AUA 2006). Atlanta, Georgia (USA). 20–25 May 2006. Level of evidence.
126 El- Gharib M. Prolene Mesh Sling in Treatment of Female Stress Urinary Incontinence. Paper presented at: XIX FIGO World Congress of Gynecology & Obstetrics (FIGO 2009), Cape Town International Convention Centre. Cape Town. 4–9 Oct 2009. Level of evidence.
127 El Hemaly A. Urethro-Vaginoplasty: An Operation Innovated for the Treatment of Stress Urinary Incontinence, SUI and Vaginal Prolapse. Paper presented at: XIX FIGO World Congress of Gynecology & Obstetrics (FIGO 2009), Cape Town International Convention Centre. Cape Town. 4–9 Oct 2009. Level of evidence.
128 Elkadry E. Functional urinary incontinence in women. Journal of Pelvic Medicine and Surgery. 2006;12(1):1-13. Level of evidence.
129 Elliott V, Dumoulin C, Martin C, et al. Physical Therapy for Persistent Postpartum Stress Urinary Incontinence: A Seven Year Follow-up Study. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
130 Elser D, Mitchell G. Twelve-Month Durability of Effectiveness of Transurethral Radiofrequency Collagen Denaturation (RenessaARG) for Treatment of Stress Urinary Incontinence in Women. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
131 Elser D, Mitchell G, Miklos J, et al. Transurethral Radiofrequency Collagen Denaturation (RenessaRG) for Treatment of Stress Urinary Incontinence in Women: Interim Urogenital Distress Inventory Results of a 36-Month Study. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
132 Emili E, Lo Cigno M, Montanari F, et al. Repeat surgery for iatrogenic urinary incontinence associated with detrusor hyperreflexia: Case report. Acta Urologica Italica. 1989;3(4 SUPPL 1):567-70. Level of evidence.
133 Everaert K, Oostra K, Kerkchaert W, et al. Urodynamic evaluation and treatment of urinary incontinence after severe brain injury. Paper presented at: 27th Annual Meeting of the International Continence Society. Yokohama (Japan). 23–26 Sep 1997. (World Meeting Number 973 0118). Level of evidence.
134 Faerber GJ. Endoscopic collagen injection therapy for elderly women with type I stress urinary incontinence. Paper presented at: American Urological Society 90th Annual Meeting. Las Vegas, NV (USA). 23–28 April 1995. (World Meeting Number 952 0772). Level of evidence.
135 Fantl JA, Bump RC, McClish DK. Mixed urinary incontinence. Urology. 1990;36(4 SUPPL):21-4. Level of evidence.
136 Fantl JA, Wyman JF, McClish DK, et al. Urinary incontinence in community-dwelling women: Clinical, urodynamic, and severity characteristics. American Journal of Obstetrics and Gynecology. 1990;162(4):946-52. Level of evidence. [pmid: 2327465].
137 Farruggia V, Orlando M, Rubino SM. The vaginal profile in 120 women with genuine stress urinary incontinence: Considerations on current therapeutic trends. Il profilo vaginale in 120 donne con ius genuina: Considerazioni sugli orientamenti terapeutici attuali. 2001;15(1 SUPPL):205-7. Level of evidence.
138 Feil G, Boehmler A, Maurer S, et al. A New Approach for Functional Treatment of Urinary Incontinence with Mesenchymal Stem Cells in a Rat Model. Paper presented at: 21st Annual Congress of the European Association of Urology (EAU 2006), Palais des Congres. Paris (France). 5–8 Apr 2006. Level of evidence.
139 Feil G, Boehmler AM, Maurer S, et al. Myogenically Differentiated Mesenchymal Stem Cells for Treatment of Urinary Incontinence in a Rat Model. Paper presented at: 2006 Annual Meeting of the American Urological Association (AUA 2006). Atlanta, Georgia (USA). 20–25 May 2006. Level of evidence.
140 Feil G, Boehmler AM, Maurer S, et al. Bone Marrow-Derived Mesenchymal Stem Cells for Functional Treatment of Urinary Incontinence in a Rat Model. Paper presented at: 32nd Annual Meeting of the European Group for Blood and Marrow Transplantation and 22nd Meeting of the EBMT Nurses Group and 5th Meeting of the EBMT Data Management Group (EBMT 2006), CCH Congress Center Hamburg. Hamburg (Germany). 19–22 Mar 2006. Level of evidence.
141 Feil G, Schafer J, Wiedemann J, et al. Cell-based Treatment Modality of Urinary Incontinence with Human Mesenchymal Stem Cells in a Nude Rat Model. Paper presented at: 2008 Annual Meeting of the American Urological Association. Orlando, Florida (USA). 17–22 May 2008. Level of evidence.
142 Ferdinandi V, De Paula F, Cappa M, et al. The role of the AMS 800 artificial sphincter in the treatment of male urinary incontinence. Acta Urologica Italica. 1989;3(4 SUPPL 1):485-6. Level of evidence.
143 Fiadjoe PKG, Holmes DM. Clinical Audit of the use of Tvtas Treatment of Stress Urinary Incontinence. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
144 Figuers CC, Boyle K-L, Caprio K. A Comparison of Pelvic Floor Muscle Activity and Urinary Incontinence between Weight-Bearing Female Athletes and Female Non-Athletes. Paper presented at: 2007 Combined Sections Meeting of the American Physical Therapy Association (CSM 2007). Boston, Massachusetts (USA). 14–18 Feb 2007. Level of evidence.
145 Fischer W. Therapeutic possibilities and choice of adequate treatment of female urinary incontinence (UI). European Journal of Obstetrics Gynecology and Reproductive Biology. 1994;55(1):43-4. Level of evidence.
146 Fischer-Rasmussen W. Transvaginal needle bladder neck suspension for stress urinary incontinence: Practicable methods but not optimal results. Acta Obstetricia et Gynecologica Scandinavica, Supplement. 1998;77(168):38-43. Level of evidence. [pmid: 9744789].
147 Foglia G, Mistrangelo E, Lijoi D, et al. Transfascial vaginal tape (TFT) in the treatment of stress urinary incontinence: One year follow-up. Transfascial vaginal tape (TFT) nel trattamento dell’incontinenza urinaria da sforzo: Follow-up a un anno. 2005;19(1 SUPPL):148-51. Level of evidence.
148 Fowler CJ. The Perspective of a Neurologist on Treatment-Related Research in Fecal and Urinary Incontinence. Gastroenterology. 2004;126(1). Level of evidence.
149 Fozzatti C, Herrmann V, Riccetto C, et al. Global Postural Reducation is an Effective Treatment for Stress Urinary Incontinence When Compared to Pelvic Floor Muscle Training and Adherence is Better. Paper presented at: 2008 Annual Meeting of the American Urological Association. Orlando, Florida (USA). 17–22 May 2008. Level of evidence.
150 Franco A, Hay D, Lee F, et al. Voiding Dysfunction and the Transobturator Approach for the Treatment of Female Stress Urinary Incontinence (Sui). Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
151 Franco A, Lee F, Wang K, et al. Evaluation of the Safety of the Transobturator Approach for the Treatment of Stress Urinary Incontinence (SUI). Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Level of evidence.
152 Freutzberg K. New therapy option in stress urinary incontinence - Tension-free vaginal tape. Neue therapieoption bei stressinkontinenz - Legen sie die blase an die leine. 2000;142(3):16. Level of evidence.
153 Fusgen I. Therapy of urinary incontinence in the elderly in general medica-practice. PHYSIOLOGIE UND PATHOPHYSIOLOGIE DER MIKTION IM ALTER. 1998;22:227-33. +338. Level of evidence.
154 Galaup JP. Urinary incontinence and prolapse. INCONTINENCE URINAIRE ET PROLAPSUS. TRAITEMENT MEDICAMENTEUX ET TRAITEMENT FONCTIONNEL. 1990;85(10):519-23. Level of evidence.
155 Galbiati F, Holopainen A, Remes A. A Mobile Telemedicine Solution Offering More Comfort and Privacy in Stress Urinary Incontinence treatment. Paper presented at: 2008 International Educational and Networking Forum for eHealth, Telemedicine and Health ICT (Med-e-Tel 2008). G. D. of Luxembourg (Luxembourg). 16–18 Apr 2008. Level of evidence.
156 Galloway NTM. Surgical treatment of urinary incontinence in geriatric women. American Journal of the Medical Sciences. 1997;314(4):268-72. Level of evidence. [pmid: 9332267].
157 Geerdes BP, Heesakkers JPFA, Heineman E, et al. Simultaneous treatment of faecal and urinary incontinence in children with spina bifida using double dynamic graciloplasty. British Journal of Surgery. 1997;84(7):1002-3. Level of evidence. [pmid: 9240148].
158 George SW, Nickel JC, Tata E, et al. Patient goal-oriented approach for the treatment of stress urinary incontinence in females. Paper presented at: American Urological Society 90th Annual Meeting. Las Vegas, NV (USA). 23–28 April 1995. (World Meeting Number 952 0772). Level of evidence.
159 Ghoniem G. Bulking Agents for Treatment of Female Stress Urinary Incontinence (SUI) Secondary to ISD. Paper presented at: 18th Annual Saudi Urological Conference. Jeddah (Saudi Arabia). 20–23 Feb 2006. Level of evidence.
160 Ghoniem G, Lapeyrolerie J, Thomas R, et al. Evaluation and treatment of urinary incontinence after artificial urinary sphincter placement. Neurourology and Urodynamics. 1990;9(2):224-5. Level of evidence.
161 Ghoniem G, Stanford E, Klutke J, et al. Efficacy Outcomes of a Low Elasticity Polypropylene Transobturator Midurethral Sling for the Treatment of Female Stress Urinary Incontinence: Final Data Combined from Two Multi-Center Prospective Clinical Studies. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
162 Giammo A, Bodo G, Castellano S, et al. The Use of Spiral MDCT (Multi Detector Computed Tomography) Scan in Proact (Adjustable Continence Therapy) Implant Failures. Paper presented at: 21st Annual Congress of the European Association of Urology (EAU 2006), Palais des Congres. Paris (France). 5–8 Apr 2006. Level of evidence.
163 Giberti C, Martorana G, Pacella M, et al. Retropubic colpocystourethropexy according to Tanagho procedure in the treatment of urinary stress incontinence. LA COLPOSOSPENSIONE RETROPUBICA SECONDO TANAGHO NEL TRATTAMENTO DELL’INCONTINENZA URINARIA DA SFORZO FEMMINILE. 1992;6(SUPPL 6):269-73. Level of evidence.
164 Giberti C, Siracusano S, Ciciliato S, et al. Transvaginal Bone-Anchored Sling (BAS) for Treatment of Stress Urinary Incontinence: Intermediate-Term Follow-Up. Paper presented at: 21st Annual Congress of the European Association of Urology (EAU 2006), Palais des Congres. Paris (France). 5–8 Apr 2006. Level of evidence.
165 Gill HS, Payne CK. Experience with collagen injection therapy in men with urinary incontinence. Paper presented at: American Urological Society 90th Annual Meeting. Las Vegas, NV (USA). 23–28 April 1995. (World Meeting Number 952 0772). Level of evidence.
166 Giraldo P. Physical Therapy Treatment for Female Urinary Incontinence: Iciq-Sf Quality of Life. Paper presented at: XIX FIGO World Congress of Gynecology & Obstetrics (FIGO 2009), Cape Town International Convention Centre. Cape Town. 4–9 Oct 2009. Level of evidence.
167 Glavind K, Hill S, Kawakami F, et al. Efficacy and Tolerability of Darifenacin in Female Patients with Overactive Bladder (OAB): A 2-Year, Open-Label Extension Study. Paper presented at: 31st Annual Meeting of the International Urogynecological Association, Athens Hilton Hotel. Athens (Greece). 6–9 Sep 2006. Level of evidence.
168 Gondry J, Gagneur O, Naepels P, et al. Treatment of stress urinary incontinence. Experience of the Gynaecology-Obstetrics Department of Amiens. Revue Francaise de Gynecologie et d’ Obstetrique. 1990;85(12):684-8. Level of evidence. [pmid: 2291051].
169 Gonzalez Garcia A, Dupla B, Fernandez Camporro J. Retropubic Tension-Free Vaginal Tape (Tvt) in the Treatment of Stress Urinary Incontinence in Women: Treatment and 4-Year Follow-up Outcomes. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
170 Gormley EA, Bloom DA, McGuire EJ, et al. Pubovaginal slings for the management of urinary incontinence in female adolescents. Journal of Urology. 1994;152(2 II):822-5. Level of evidence. [pmid: 8022024].
171 Granata P, Napolitano V, Bifulco G, et al. TVT (Tension free Vaginal Tape) associated with cystopexy and correction of rectocele in patients with stress urinary incontinence (SUI). TVT (Tension free Vaginal Tape) associata a cistopessi ed a correzione di rettocele in pazienti affette da incontinenza urinaria da sforzo (IUS). 2000;14(3):111-5. Level of evidence.
172 Grechi G, Vincenzi R, Marmorato G, et al. Mini-invasive treatment of female stress urinary incontinence from urethral hypermobilty. Comparison between retropubic access and transobturator. Trattamento mininvasivo dell’incontinenza urinaria da sforzo femminile da ipermobilità uretrale. Confronto tra accesso retropubico e transotturatorio. 2005;19(1 SUPPL):184-6. Level of evidence.
173 Green DF, Lytton B. Comparison of endoscopic suspension of the vesical neck versus anterior urethropexy for the treatment of stress urinary incontinence. Paper presented at: AUA 1986 Eighty-First Annual Meeting. New York, NY (USA). 18–22 Mar 1986. (World Meeting Number 862 0424). Level of evidence.
174 Grise P, Serment G, Costa P, et al. Efficacy and Safety of a Low Elasticity Polypropylene Transobturator Midurethral Sling in the Treatment of Female Stress Urinary Incontinence in a Large Multi-Center European Registry with Mid-Term Follow-Up. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
175 Gruenwald IE, Rosen T, Vardi Y. Results of biofeedback treatment for urinary incontinence in the community. Paper presented at: 27th Annual Meeting of the International Continence Society. Yokohama (Japan). 23–26 Sep 1997. (World Meeting Number 973 0118). Level of evidence.
176 Guercio E, Gatti M, Perino M, et al. Tension-free vaginal tape in the treatment of urinary incontinence associated with genital prolapse. La TVT nel trattamento dell’incontinenza urinaria associata a prolasso genitale. 2001;15(1 SUPPL):77-9. Level of evidence.
177 Guercio S, Guercio E, Ambu A, et al. Treatment of stress urinary incontinence with I-STOP suburethral sling. Trattamento dell’incontinenza urinaria da sforzo con benderella sottouretrale I-stop. 2006;20(2):310-1. Level of evidence.
178 Guizhu W, Yanfeng S. Adipose-Derived Stem Cell Transplantation for the Treatment of Stress Urinary Incontinence. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
179 Gurung P, Attar K, Hameed R, et al. Long Term Outcomes of the Treatment of Male Stress Urinary Incontinence with Polydimethylsiloxane Following Spinal Cord Injury. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
180 Guys JM, Fakhro A, Louis-Borrione C, et al. Endoscopic treatment of urinary incontinence: Long-term evaluation of the results. Journal of Urology. 2001;165(6 II SUPPL):2389-91. Level of evidence. [pmid: 11371983].
181 Haessler AL, Nguyen JN, Bhatia NN. Functional Electrical Stimulation for the Treatment of Female Urinary Incontinence: Attitudes and Practices of American Urogynecologic Society Physicians. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
182 Hage B, Hanna S, Schmutz G, et al. Male Sling for Moderate to Severe Stress Urinary Incontinence: Efficacy and Mechanism. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Level of evidence.
183 Hagemeier T, Albersmeyer H, Blau U. Efficacy and Safety of Dextranomer/Hyaluronic-Acid Polymer (Zuidexr) a Minimally Invasive Therapy for Stress Urinary Incontinence in Adult Women. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
184 Hagglof B, Andren O, Bergstrom E, et al. Self-esteem in children with nocturnal enuresis and urinary incontinence: Improvement of self-esteem after treatment. European Urology. 1998;33(SUPPL 3):16-9. Level of evidence. [pmid: 9599731].
185 Han H, Wattanayingcharoenchai R, Lee L, et al. Tension Free Vaginal Tape-Obturator (TVT-O) for the Treatment of Female Stress Urinary Incontinence: 1 Year Follow-Up. Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Level of evidence.
186 Han J-Y, Doo CK, Kim J-Y, et al. The Changes of Voiding and Storage Function after the Tension-Free Vaginal Tape Procedure for Female Stress Urinary Incontinence: Five-Year Outcomes. Paper presented at: 2008 Annual Meeting of the American Urological Association. Orlando, Florida (USA). 17–22 May 2008. Level of evidence.
187 Handel LN, Ashok S, Shapiro AM, et al. Multicenter Experience with Tandem Cuff Artificial Urinary Sphincter as Primary and Salvage Treatment for Male Urinary Incontinence. Paper presented at: 2006 Annual Meeting of the American Urological Association (AUA 2006). Atlanta, Georgia (USA). 20–25 May 2006. Level of evidence.
188 Hansson S. Urinary incontinence in children and associated problems. Scandinavian Journal of Urology and Nephrology, Supplement. 1992;(141):47-57. Level of evidence. [pmid: 1609252].
189 Harris NM, Swithinbank L, al Hayek S, et al. Can Maximum Urethral Closure Pressure be Used to Predict Outcome of Surgical Treatment of Stress Urinary Incontinence. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
190 Harris RL, Yancey CA, Wiser WL, et al. Comparison of anterior colporrhaphy and retropubic urethropexy for patients with genuine stress urinary incontinence. American Journal of Obstetrics and Gynecology. 1995;173(6):1671-5. Level of evidence. [pmid: 8610743].
191 Harvey M, Day A. The Treatment of Stress Urinary Incontinence Using an Incontinence Ring: A Randomized, Cross-over Trial. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
192 Harvey M, Day A. The Treatment of Stress Urinary Incontinence Using an Incontinence Ring: A Randomized, Crossover Trial. Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Level of evidence.
193 Harvey MA, Johnston SL. A Randomized, Single-Blind Prospective Trial Comparing Pelvic Floor Physiotherapy with Biofeedback Versus Weighted Vaginal Cones in the Treatment of Female Genuine Stress Urinary Incontinence: A Pilot Study. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
194 Hay D, Franco A, Lee F, et al. The Trans-Obturator Approach for the Treatment of Female Stress Urinary Incontinence (Sui): Efficacy and Morbidity. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
195 Henry GD. Perineal Approach for Implantation of an Artificial Urinary Sphinctor Appears to Control Male Stress Urinary Incontinence Better than the Penoscrotal Approach. Paper presented at: 2006 Annual Meeting of the American Urological Association (AUA 2006). Atlanta, Georgia (USA). 20–25 May 2006. Level of evidence.
196 Henry GD, Cornell RJ, Flynn BJ, et al. A Multicenter Study on Perineal Versus Penoscrotal Approach for Implantation of an Artificial Urinary Sphincter: Cuff Size and Control of Male Stress Urinary Incontinence. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Level of evidence.
197 Hislop J. Questionable Reproducibility of Systematic Reviews: a Case-Study on Treatment for Stress Urinary Incontinence. Paper presented at: 6th Annual Meeting of Health Technology Assessment International (HTAi 2009), Suntec Singapore International Convention Centre. Singapore. 21–24 Jun 2009. Level of evidence.
198 Hislop J. Non-surgical Treatment for Women with Stress Urinary Incontinence: a Systematic Review Incorporating a Mixed Treatment Comparison Analysis. Paper presented at: 6th Annual Meeting of Health Technology Assessment International (HTAi 2009), Suntec Singapore International Convention Centre. Singapore. 21–24 Jun 2009. Level of evidence.
199 Hohales Alfonso FJ. Critical analysis of medical and surgical tretment of urinary incontinence. Analisis critico del tratamiento medico y quirurgico de la incontinencia urinaria. 2000;4(5):237-40. Level of evidence.
200 Horbach NS. New advances in the nonsurgical management of stress urinary incontinence. Advanced Studies in Medicine. 2004;4(3 C). Level of evidence.
201 Huang YL, Chen HY, Rau YL, et al. Computer-aided diagnosis of stress urinary incontinence with vector-based perineal ultrasound using neural networks. Computer-Assisted Radiology and Surgery. 2007;2(1 SUPPL). [doi: 10.1007/s11548-007-0117-1]. Level of evidence.
202 Huang YL, Shiu JJ, Chen HY. Computer-Aided Diagnosis of Stress Urinary Incontinence with Vector-Based Perineal Ultrasound using Neural Networks. Paper presented at: 9th International Workshop on Computer-Aided Diagnosis (CAD). ICC Berlin, Berlin (Germany). 27–30 Jun 2007. Level of evidence.
203 Hui Z. Stem Cell-Seeded Silk Sling for Stress Urinary Incontinence Treatment in a Rat Model. Paper presented at: XIX FIGO World Congress of Gynecology & Obstetrics (FIGO 2009), Cape Town International Convention Centre. Cape Town. 4–9 Oct 2009. Level of evidence.
204 Hunt M, Von Konsky B, Venkatesh S, et al. Bayesian networks and decision trees in the diagnosis of female urinary incontinence. Paper presented at: Chicago 2000: World Congress on Medical Physics and Biomedical Engineering. Chicago, IL (USA). 23–28 Jul 2000. (World Meeting Number 000 5335). Level of evidence.
205 Hurtado EA, McCrery RJ, Appell RA. Complications of Ethylene Vinyl Alcohol Copolymer as an Off-Label Intra-Urethral Bulking Agent in Men with Stress Urinary Incontinence. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Level of evidence.
206 Ishibashi T, Akiyoshi M, Kato K, et al. Stress Urinary Incontinence Was Not Influenced by Hormone Replacement Therapy, but Had an Affect on Peri-Menopausal Quality of Life. Paper presented at: 8th European Congress on Menopause (EMAS 2009), ExCel Centre. London (UK). 16–20 May 2009. Level of evidence.
207 ISRCTN01717074. The treatment of urinary incontinence in stroke patients. Not eligible exposure.
208 ISRCTN15411586. The measurement of urinary incontinence via survey questionnaires. Not eligible exposure.
209 ISRCTN15553880. Effects of introducing a specialised nurse in the care of community-dwelling women suffering from urinary incontinence. Not eligible exposure.
210 ISRCTN16772662. Group treatment: an acceptable and effective method of physiotherapy provision for female urinary incontinence?. Not eligible exposure.
211 ISRCTN23418270. A randomised controlled trial of educational group sessions and conventional individual management in the physiotherapeutic treatment of female urinary incontinence (FUI). Not eligible exposure.
212 ISRCTN27633617. A pilot study to evaluate the effectiveness of dynamic lumbo-pelvic stability training as a treatment strategy for women with stress incontinence: a randomised controlled trial. Not eligible exposure.
213 ISRCTN29863839. A prospective, randomised, controlled trial to evaluate the efficacy and safety of endoscopic choroid plexus coagulation with third ventriculostomy in the treatment of idiopathic Normal Pressure Hydrocephalus. Not eligible exposure.
214 ISRCTN31004502. A randomised, double blind, placebo controlled, crossover trial of the adjuvant properties of imipramine for the overactive bladder. Not eligible exposure.
215 ISRCTN34759911. Colposuspension or tension free vaginal tape with anterior repair for urinary incontinence and prolapse: a pilot study. Not eligible exposure.
216 ISRCTN37726767. A prospective randomised controlled trial of pelvic floor exercises plus biofeedback versus pelvic floor exercises alone in treating stress urinary incontinence. Not eligible exposure.
217 ISRCTN39853232. A phase II, multi-centre, double-blind, placebo-controlled, 2-way cross-over study to evaluate efficacy, plasma concentrations and safety of 0.25 mL of 20 % w/w PSD503 for topical application in female volunteer patients with stress urinary incontinence. Not eligible exposure.
218 ISRCTN44339585. Laparoscopic Treatment for Female Urinary Incontinence. Not eligible exposure.
219 ISRCTN59388318. Re-education of the pelvic floor in women with urinary stress incontinence. Not eligible exposure.
220 ISRCTN62722772. The effects of involving a nurse practitioner in primary care for adult patients with urinary incontinence. Not eligible exposure.
221 ISRCTN66713401. Pilot study for the comparison of drug treatment with conservative treatment for people with overactive bladders. Not eligible exposure.
222 ISRCTN71247587. Autologous myoblasts and fibroblasts versus collagen for treatment of stress urinary incontinence in women: a randomised trial. Not eligible exposure.
223 ISRCTN97337606. A study to compare bladder function of healthy Asian and Caucasian women. Not eligible exposure.
224 ISRCTN97355181. A double-blind, placebo controlled study to assess the safety and preliminary efficacy of PSD506 in treatment-naïve or previously treated (washed out) patients with symptoms of overactive bladder. Not eligible exposure.
225 Iuliano A, Roselli D, Paesano PG, et al. Tension free techniques in the treatment of stress urinary incontinence: Surgical techniques in comparison and follow-up. Tecniche “tension free” nel trattamento dell’incontinenza urinaria da sforzo: Tecniche chirurgiche a confronto e follow-up. 2005;19(1 SUPPL):187-9. Level of evidence.
226 Izzat F, Constantine G. Trans-Obturator Tape (TOT) Procedures: A Report on Our Experience after Two Years in Treatment of Female Stress Urinary Incontinence. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
227 Jacquetin B. ‘TVT procedure’ for surgical treatment of female urinary incontinence. Utilisation du << TVT >> dans la chirurgie de l’incontinence urinaire feminine. 2000;29(3):242-7. Level of evidence.
228 Jarmy-Di Bella Z, Bianchi A, Castro R, et al. Randomised Trial of TVT-O and TVT-S for the Treatment of Stress Urinary Incontinence. Preliminary Study. Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Level of evidence.
229 Jeon JH. A Short-Term Retrospective Study Comparing Tension-Free Vaginal Tape and Transoburator Tape for Surgical Treatment of Female Stress Urinary Incontinence. Paper presented at: XVIII FIGO World Congress of Gynecology and Obstetrics (FIGO 2006), Kuala Lumpur Convention Centre (KLCC). Kuala Lumpur (Malaysia). 5–10 Nov 2006. Level of evidence.
230 Johnson TM Ii, Busby-Whitehead J. Diagnostic assessment of geriatric urinary incontinence. American Journal of the Medical Sciences. 1997;314(4):250-6. Level of evidence. [pmid: 9332264].
231 Jordan O, Defabiani N, Caviezel A, et al. Novel injectable urethral bulking agents for the treatment of urinary incontinence. Paper presented at: 18th European Conference on Biomaterials. Stuttgart (Germany). 1–4 Oct 2003. (World Meeting Number 000 7087). Level of evidence.
232 Jordan O, Doelker E, Defabiani N, et al. Novel injectable urethral bulking agents for the treatment of urinary incontinence. Journal of Materials Science: Materials in Medicine. 2004;15(4):519-22. Level of evidence. [pmid: 15332628].
233 JPRN-JapicCTI-050025. CS-801 phase 3 comparative study. Not eligible exposure.
234 JPRN-JapicCTI-050026. CS-801 phase 3 long-term study. Not eligible exposure.
235 JPRN-JapicCTI-070432. Long-term study of imidafenacin in patients with overactive bladder. Not eligible exposure.
236 JPRN-JapicCTI-090874. A Phase 2 Study of TRK-130 in Patients With Overactive Bladder. Not eligible exposure.
237 Jung BJ, Yum SH, Choi YS, et al. A Prospective Trial Comparing Tension-Free Vaginal Tape and Transobturator Vaginal Tape Inside-Out for the Surgical Treatment of Female Stress Urinary Incontinence: 1-Year Follow-Up. Paper presented at: 2006 Annual Meeting of the American Urological Association (AUA 2006). Atlanta, Georgia (USA). 20–25 May 2006. Level of evidence.
238 Jung H, Song P, Kim J, et al. Five-Year Outcomes of the Iris Procedure for Treatment of Female Stress Urinary Incontinence: Comparison with Tvt Procedure. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
239 Kamel A. Long-Term Results of the Tension-Free Vaginal Tape (Tvt) Procedure for the Treatment of Stress Urinary Incontinence. The Egyptian Experience. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
240 Kaplan E, Sazykina E, Korshunov M. The Advantages of Suburethral Readjustable Slings for the Treatment of Stress Urinary Incontinence in Women. Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Level of evidence.
241 Kaya C, Pirincci N, Kanberoglu H, et al. Periurethral Prolene Mesh Supported Vaginal Wall Sling: New Periurethral Fibrosis Procedure for the Treatment of Stress Urinary Incontinence. Paper presented at: 21st Annual Congress of the European Association of Urology (EAU 2006), Palais des Congres. Paris (France). 5–8 Apr 2006. Level of evidence.
242 Kelm-Kahl I. The 32nd Annual Meeting of the International Continence Society in Heidelberg. Successful treatment of urinary and fecal incontinence. 32. Jahrestagung der International Continence Society, Heidelberg. Urin-und stuhlinkontinenz erfolgreich behandeln. 2002;127(44):2306-7. Level of evidence.
243 Kennelly M, Siegel S, De Ridder D. An Early Clinical Evaluation of the MiniArc Performed Under General or Local Anesthesia for the Treatment of Stress Urinary Incontinence. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
244 Kieran K, Hollenbeck BK, Wei JT, et al. Complications Following Surgical Intervention for Urinary Incontinence in Men: A National Perspective. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Level of evidence.
245 Kilinc M. To Form Urethra-Vesical Angle for Treatment of Female Stress Urinary Incontinence: A Novel Technique. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
246 Kim DK, Jankowski R, Pruchnic R, et al. The In Vitro and In Vivo Evaluation of Lidocaine on Rat Muscle-Derived Cells for Treatment of Stress Urinary Incontinence. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Level of evidence.
247 Kim H, Yoshida H, Suzuki T. Exercises Treatment to Reduce the Urine Leakage in Elderly Community-Dwelling Japanese Women with Stress, Urge, and Mixed Urinary Incontinence. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
248 Klutke C, Williams E, Ferguson G, et al. Transgluteal Placement of a Pudendal Nerve Stimulator for the Treatment of Refractory Urge Urinary Incontinence: Description and Technique. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
249 Kobl H, Hanzal E, Bernaschek G. Sonographic diagnosis of female urinary incontinence. SONOGRAPHISCHE DIAGNOSTIK DER WEIBLICHEN HARNINKONTINENZ. 1991;250(1–4):48-9. Level of evidence.
250 Kocjancic E, Carone R, Bodo G, et al. 36-Month follow-up of adjustable continence therapy (ACT) in female stress urinary incontinence due to intrinsic sphincter deficiency. Follow-up di 36 mesi con adjustable continence therapy (ACT) nell’incontinenza da sforzo femminile dovuta a deficit sfinterico intrinseco. 2005;19(1 SUPPL):223-4. Level of evidence.
251 Kocjancic E, Crivellaro S, Ranzoni S, et al. Italian Single-Centre Evaluation of Adjustable Continence Therapy for the Treatment of Female Stress Urinary Incontinence: 4 Year Follow-Up. Paper presented at: 21st Annual Congress of the European Association of Urology (EAU 2006), Palais des Congres. Paris (France). 5–8 Apr 2006. Level of evidence.
252 Kocjancic E, Crivellaro S, Ranzoni S, et al. 24-Month follow-up for sling transobturator in the surgical treatment of stress urinary incontinence. Follow-up di 24 mesi per le sling tansotturatorie nel trattamento chirurgico dell’incontinenza da sforzo femminile. 2005;19(1 SUPPL):212. Level of evidence.
253 Kocjancic E, Crivellaro S, Ranzoni S, et al. Adjustable Continence Therapy as a Surgical Treatment of Recurrent Female Urodynamic Stress Urinary Incontinence. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Level of evidence.
254 Kocjancic E, Crivellaro S, Ranzoni S, et al. Six Year Results of the Adjustable Continence Therapy (ACT) for Recurrent Female Stress Urinary Incontinence. Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Level of evidence.
255 Kocjancic E, Crivellaro S, Ranzoni S, et al. The adjustable continence therapy for the treatment of recurrent female urodynamic stress urinary incontinence-4 year results. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
256 Kocjancic E, Stecco A, Guglielmetti S, et al. MR imaging evaluation of minimal invasive surgery for stress urinary incontinence in women. Valutazione della chirurgia mini-invasiva modulabile dell’incontinenza urinaria da sforzo femminile mediante risonanza magnetica nucleare. 2001;15(1 SUPPL):138-9. Level of evidence.
257 Kocjiancic E, Crivellaro S, Tosco L, et al. Implantation of Adjustable Continence Therapy (Act) for Treatment of Stress Urinary Incontinence in Adults with Neobladders. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
258 Kocjiancic E, Crivellaro S, Tosco L, et al. Long Term Results of the Adjustable Continence Therapy (ActRG) for Recurrent Female Stress Urinary Incontinence. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
259 Koelbl H. Primary Surgical Treatment of Stress Incontinence. Paper presented at: 19th European Congress of Obstetrics and Gynaecology, Lingotto Congress Center. Torino (Italy). 5–8 Apr 2006. Level of evidence.
260 Koufomichail BK, Avgerinos AA, Arkomani VA, et al. Long-Term Results in Efficacy after Treatment of Stress Urinary Incontinence with Tvt. An Experience of 88 Cases. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
261 Krcmar M, Krofta L, Otcenasek M, et al. Comparing Tension-Free Vaginal Tape and Transobturator Vaginal Tape inside-Out for Surgical Treatment of Stress Urinary Incontinence: Prospective Randomized Trial, 1-Year Follow-Up. Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Level of evidence.
262 Krofta L, Feyereisl J, Krcmar M, et al. One Year Prospective Follow-up of the TVT-S Procedure for Treatment of Stress Urinary Incontinence. Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Level of evidence.
263 Kronner KM, Rink RC, Simmons G, et al. Artificial urinary sphincter in the treatment of urinary incontinence: Preoperative urodynamics do not predict the need for future bladder augmentation. Journal of Urology. 1998;160(3 II):1093-5. Level of evidence. [pmid: 9719283].
264 Kuschel S, Schuessler B. Results of a Prospective Observational Study on Function and Safety of the Tot-SafyreRG (TOT/S), a Composite Silicone-Polypropylene Sling System for the Treatment of Stress Urinary Incontinence (SUI). Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
265 Langford C. Do Women have Realistic Expectations of Treatment for Stress Urinary Incontinence?. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
266 Laungani RG, Seleno N, Hoffman T, et al. The Effect of Laparoscopic Gastric Bypass Surgery on Urinary Incontinence in Morbidly Obese Women. Paper presented at: 2008 Annual Meeting of the American Urological Association. Orlando, Florida (USA). 17–22 May 2008. Level of evidence.
267 Lazzeri M, Costantini E, Giannantoni A, et al. 1-Hour Pad Test has Low Predictive Value in the Diagnosis of Women with Urinary Incontinence. Paper presented at: 2008 Annual Meeting of the American Urological Association. Orlando, Florida (USA). 17–22 May 2008. Level of evidence.
268 Leanza V, Gasbarro N, Garozzo V. Mininvasive surgery for stress urinary incontinence: Retropubic route. Urogynaecologia International Journal. 2005;19(1 SUPPL):190-6. Level of evidence.
269 Leanza V, Torrisi G. The last surgical way for solving stress urinary incontinence (SUI): The prepubic route. Urogynaecologia International Journal. 2005;19(1 SUPPL):378-84. Level of evidence.
270 Lee JN, Koh CJ, Lee CS, et al. Early Phase I II Clinical Trial Results for Human Cord Blood Stem Cell Injection Therapy for Stress Urinary Incontinence. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Level of evidence.
271 Lee K, Lee Y, Seo J, et al. A Prospective Multicenter Randomized Study of ‘U’ and ‘H’ Approach of Tvt-Secur Procedure for the Treatment of Female Stress Urinary Incontinence: One-Year Follow-Up. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
272 Lee KS. Duloxetine versus Placebo for the Treatment of Women with Stress Predominant Urinary Incontinence in Korea. Paper presented at: XVIII FIGO World Congress of Gynecology and Obstetrics (FIGO 2006), Kuala Lumpur Convention Centre (KLCC). Kuala Lumpur (Malaysia). 5–10 Nov 2006. Level of evidence.
273 Lee Y, Lee H, Lee K, et al. Transurethral Injection of Bulking Agent for the Treatment of Recurrent or Persistent Female Stress Urinary Incontinence after Mid-Urethral Sling. Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Level of evidence.
274 Leerasiri P, Han HC, Lee LC, et al. A Retrospective Review of Patients who Underwent Tension-free Vaginal Tape (TVT) Procedure With or Without Concurrent Surgery in the Treatment of Urinary Incontinence. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
275 Lei Z, Yinghe C. Tvt-O Procedure for the Treatment of Stress Urinary Incontinence. Paper presented at: 26th World Congress of Endourology (WCE 26), Shanghai International Convention Center (SICC). Shanghai (China). 30 Nov–3 Dec 2008. Level of evidence.
276 Leroi AM, Michot F, Grise P, et al. Effect of sacral nerve stimulation in patients with fecal and urinary incontinence. Diseases of the Colon and Rectum. 2001;44(6):779-89. Level of evidence. [pmid: 11391135].
277 Lewi H, Sheriff M. Endoscopic technique for treatment of female stress urinary incontinence with macroplastique implants: A training video. Paper presented at: European Association of Urology XIVth Congress. Stockholm (Sweden). 21–25 Mar 1998. (World Meeting Number 981 0518). Level of evidence.
278 Lewis JB, Ng A, onnor RC, et al. Are there Differences between Women with Urge Predominant and Stress Predominant Mixed Urinary Incontinence?. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Level of evidence.
279 Li Y, Cai X, Glance L, et al. Urinary Incontinence in Community-Dwelling Older Women: Does Socioeconomic Status Affect Help Seeking and Treatment?. Paper presented at: 135th Annual Meeting and Exposition of the American Public Health Association (APHA 2007), Washington Convention Center (WCC). Washington, DC (USA). 3–7 Nov 2007. Level of evidence.
280 Liang Z. Laparoscopic burch colposuspension for the treatment of stress urinary incontinence. Paper presented at: XVII FIGO World Congress of Gynecology and Obstetrics. Santiago (Chile). 2–7 Nov 2003. (World Meeting Number 000 7240). Level of evidence.
281 Lijoi D, Gorlero F, Mistrangelo E, et al. TVT secur for the surgical treatment of stress urinary incontinence: Preliminary data. TVT-secur per il trattamento chirurgico dell’incontinenza urinaria da sforzo: Dati preliminari. 2007;21(2):14-8. Level of evidence.
282 Lin A. Duloxetine versus Placebo for the Treatment of Women with Stress Predominant Urinary Incontinence in Taiwan. Paper presented at: XVIII FIGO World Congress of Gynecology and Obstetrics (FIGO 2006), Kuala Lumpur Convention Centre (KLCC). Kuala Lumpur (Malaysia). 5–10 Nov 2006. Level of evidence.
283 Long C, Tsai E. Ultrasonographic and Urodynamic Comparison of Tension-Free Vaginal Tape and Transobturator Tape Procedure for the Treatment of Stress Urinary Incontinence. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
284 Lopez S, Daures JP, Tintrelin-Jacquez I, et al. Long-term results of rehabilitation of urinary incontinence in women. RESULTATS A DISTANCE DE LA REEDUCATION DE L’INCONTINENCE URINAIRE DE LA FEMME. 1990;33(1):93-8. Level of evidence.
285 Lose G. Aspects on the actual practice of surgical management of urinary incontinence in Norway and Finland. Acta Obstetricia et Gynecologica Scandinavica, Supplement. 1998;77(168):25-8. Level of evidence. [pmid: 9744786].
286 Lose G, Sorensen H, Al-Singary W, et al. An Open Multicenter Study of Polyacrylamide Hydrogel (BulkamidRG) for the Treatment of Stress and Mixed Urinary Incontinence. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
287 Loughlin KR. Endoscopic fascial sling for treatment of female stress urinary incontinence. Paper presented at: American Urological Society 90th Annual Meeting. Las Vegas, NV (USA). 23–28 April 1995. (World Meeting Number 952 0772). Level of evidence.
288 Lucioni A, Govier F, Kobashi K. Salvage Option for Treatment of Stress Urinary Incontinence after a Failed Sling or Bladder Neck Suspension: The Bone-Anchored Sling. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
289 Lykkebo A, Sorensen T. Fluid Intake, Body Mass Index and Quality of Life before and after Treatment of Patients with Urinary Incontinence. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
290 Madill SJ, McLean L. A contextual model of pelvic floor muscle defects in female stress urinary incontinence: A rationale for physiotherapy treatment. 2007;1101:335-60. Level of evidence.
291 Maffiolini M. Transobturator sling with polypropylene prosthesis: New mini-invasive technique for the treatment of stress urinary incontinence. Sling retrotturatoria con protesi di polipropilene: Nuova tecnica mininvasiva per il trattamento dell’incontinenza urinaria da sforzo. 2005;19(1 SUPPL):197-8. Level of evidence.
292 Mahboub M, Keshvari M, Taghavi R, et al. I.V.S.: A Successful Technique in Treatment of the Patients with Stress Urinary Incontinence. Paper presented at: 26th World Congress of Endourology (WCE 26), Shanghai International Convention Center (SICC). Shanghai (China). 30 Nov–3 Dec 2008. Level of evidence.
293 Maher R, Crowe L, Caulfield B. A Novel Externally Applied Neuromuscular Stimulator for the Treatment of Stress Urinary Incontinence-a Pilot Study. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
294 Mainprize TC. Diagnosis in urinary incontinence. Clinical Obstetrics and Gynecology. 1990;33(2):308-14. Level of evidence. [pmid: 2190734].
295 Makunde J, Andreasen J, Looms D. Cost-Effectiveness of outside-in Transobturator Slings (Tot) Compared to Retropubic Slings (Tvt) for Treatment of Female Stress Urinary Incontinence. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
296 Manieri C, Robimarga C, Vicentini C, et al. Unsuccesfull surgical treatment of stress urinary incontinence in female patients: Predictive value of urodynamic study. INSUCCESSI NELLA TERAPIA CHIRURGICA DELL’INCONTINENZA URINARIA DA SFORZO FEMMINILE: VALORE PREDITTIVO DELLO STUDIO URODINAMICO. 1992;6(SUPPL 1):157-60. Level of evidence.
297 Manning J, Eyers AA, Korda A, et al. Is there an association between fecal incontinence and lower urinary dysfunction?. Diseases of the Colon and Rectum. 2001;44(6):790-8. Level of evidence. [pmid: 11391137].
298 Marconi L, Marrai R, Serri F, et al. TVT-SECUR: Our experience in the treatment of female urinary incontinence isolated from or associated to utero-vaginal prolapse. TVT-SECUR: La nostra esperienza nel trattamento dell’incontinenza urinaria femminile isolata o associata a prolasso utero-vaginale. 2008;22(2):94-6. Level of evidence.
299 Maroto JR, Gorraiz MO, Chaparro LP, et al. TVA Adjustable Mesh for Surgical Treatment of Female Stress Urinary Incontinence. Paper presented at: 2008 Annual Meeting of the American Urological Association. Orlando, Florida (USA). 17–22 May 2008. Level of evidence.
300 Marsh H, Blick C, Foley SJ. Leave Stress in the Office. Zuidex(TM), a Walkthrough Treatment for Stress Urinary Incontinence. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
301 Marturano M, Paparella R, Scarpa A, et al. Nine Vaginal Erosions in the Transobturatory Surgical Treatment of 215 Cases of Female Stress Urinary Incontinence: 30 Months of Experience. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
302 Mayer RD, Dmochowski RR, Appell RA. A 52-Week Trial of Calcium Hydroxylapatite vs. Bovine Dermal Collagen for Treatment of Stress Urinary Incontinence. Paper presented at: 2006 Annual Meeting of the American Urological Association (AUA 2006). Atlanta, Georgia (USA). 20–25 May 2006. Level of evidence.
303 McAleer H, Tutrone R. Biofeedback/electrical stimulation therapy in the management of urinary incontinence in a clinical urology practice. Paper presented at: American Urological Society 90th Annual Meeting. Las Vegas, NV (USA). 23–28 April 1995. (World Meeting Number 952 0772). Level of evidence.
304 McClain C, Neville C. Treatment of Urinary Incontinence Post Stroke: An Ethics Case Study. Paper presented at: 2007 Combined Sections Meeting of the American Physical Therapy Association (CSM 2007). Boston, Massachusetts (USA). 14–18 Feb 2007. Level of evidence.
305 McLean L, Madill S, Harvey M. Differences in the relationship between pelvic floor muscle activation and intravaginal pressure during coughing between women with and without stress urinary incontinence. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
306 Mehdizadeh JF, Subak LL, Creasman J, et al. Risk Factors Vary by Type of Urinary Incontinence: Results of a Population Based Study. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Level of evidence.
307 Melo A, Costa F, Mota L, et al. Transobturator vs Retropubic Midurethral Slings in the Treatment of Female Stress Urinary Incontinence. Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Level of evidence.
308 Meschia M, Baccichet R, Riva D, et al. Comparison between two single incision minimally invasive procedures, MiniArc and Needleless, for the treatment of primary stress urinary incontinence. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
309 Meschia M, Barbacini P, Pifarotti P, et al. TVT secur: a minimally invasive procedure for the treatment of primary stress urinary incontinence. One year data from a multicenter prospective trial. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
310 Meschia M, Barbacini P, Pifarotti P, et al. Multicenter prospective trial of TVT secur for the treatment of primary stress urinary incontinence. Urogynaecologia International Journal. 2008;22(2):108-11. Level of evidence.
311 Meschia M, Pifarotti P, Bernasconi F, et al. Multicenter Randomized Trial of Tension-Free Vaginal Tape (TVT) and Trans-Obturator In-Out Technique (TVT-O) for the Treatment of Stress Urinary Incontinence. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
312 Michel M, Methfessel D, Minarzyk A, et al. Safety and Tolerability of Duloxetine in the Treatment of Female Stress Urinary Incontinence (Sui) in General Practice in Germany - Results from a Large Observational Study. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
313 Miranda V, Bortolini M, Alarab M, et al. Transobturator Tape for the Treatment of Stress Urinary Incontinence: Peri-Operative Complications. Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Level of evidence.
314 Misseri R, Casale AJ, Cain MP, et al. Alternative uses of dextranomer/hyaluronic acid copolymer: The efficacy of bladder neck injection for urinary incontinence. Journal of Urology. 2005;174(4 II):1691-4. Level of evidence. [pmid: 16148683].
315 Mistrangelo E, Nadalini C, Esposito F, et al. Tension adjustable transobturator urethral suspension in the treatment of urinary incontinence from intrinsic urethral sphincter deficiency. Uretrosospensione transotturatoria a tensione regolabile (TOA-A.M.I.) nel trattamento dell’incontinenza urinaria da deficit dello sfintere intrinseco dell’uretra. 2006;20(2):171-2. Level of evidence.
316 Montero A, Poza J, Gracia M, et al. Section and Partial Removal of Tension-Free Vaginal Tape Used in the Surgical Treatment of Stress Urinary Incontinence. Causes and Clinical Results. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
317 Moore JL, Neville CE. Treatment of Urinary Incontinence Following Spinal Cord Injury with Traditional Physical Therapy Techniques: A Case Report. Paper presented at: 2007 Combined Sections Meeting of the American Physical Therapy Association (CSM 2007). Boston, Massachusetts (USA). 14–18 Feb 2007. Level of evidence.
318 Moore RD, Miklos J, Knoll LD, et al. Monarc<FONT SIZE=-1>@@uTM@</FONT> Transobturator Sling for the Treatment of Stress Urinary Incontinence: A Prospective, Multi-Center Study with One Year Follow-Up. Paper presented at: 2006 Annual Meeting of the American Urological Association (AUA 2006). Atlanta, Georgia (USA). 20–25 May 2006. Level of evidence.
319 Mostwin JL. Expanding treatment options for stress urinary incontinence. Advanced Studies in Medicine. 2003;3(8 E). Level of evidence.
320 Mourad S. Surgical Treatment of ISD with or Without Stress Urinary Incontinence. Paper presented at: 18th Annual Saudi Urological Conference. Jeddah (Saudi Arabia). 20–23 Feb 2006. Level of evidence.
321 Nacu L. Cord Blood Cells in Stress Urinary Incontinence Treatment. Paper presented at: XIX FIGO World Congress of Gynecology & Obstetrics (FIGO 2009), Cape Town International Convention Centre. Cape Town. 4–9 Oct 2009. Level of evidence.
322 Nager CW. Design of a randomized clinical trial comparing the modified burch colposuspension and autologous fascia sling procedures for stress urinary incontinence (SUI). Paper presented at: 23rd Annual Meeting of the American Urogynecologic Society. San Fracisco, CA (USA). 17–19 Oct 2002. (World Meeting Number 000 6467). Level of evidence.
323 Nam SJ, Ryu CS, Kim K. Comparison of Tvt and Tvt-O for the Treatment of Stress Urinary Incontinence. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
324 Natal Jorge RM, Parente MPL, Mascarenhas T, et al. Numerical Simulation of the Behaviour of the Pelvic Floor Muscle by using the Finite Element Method. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
325 Natale F, Cristini C, Travaglia S, et al. Perineal rehabilitation in the treatment of female urinary incontinence: 6 year follow-up. Acta Urologica Italica. 1996;10(4):267-8. Level of evidence.
326 Natale F, Cristini C, Trucchi A, et al. Perineal rehabilitation in the treatment of urinary incontinence in female patients. LA RIABILITAZIONE DEL PIANO PERINEALE NEL TRATTAMENTO DELL’INCONTINENZA URINARIA FEMMINILE. 1992;6(SUPPL 1):289-92. Level of evidence.
327 Nataluk EA, Assimos DG, Kroovand RL. Collagen injections for treatment of urinary incontinence secondary to intrinsic sphincter deficiency. Journal of Endourology. 1995;9(5):403-6. Level of evidence. [pmid: 8580941].
328 Naumann G, Albrich S, Koelbl H, et al. Short Term Efficacy of the Fully Adjustable Single Incision Sling Ajust for the Treatment of Stress Urinary Incontinence. Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Level of evidence.
329 Nazemi TM, Govier FE, Yamada BS, et al. Mean Three Year Follow-Up of the Sparcac Sling for the Treatment of Stress Urinary Incontinence. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Level of evidence.
330 Nazemi TM, Govier FE, Yamada BS, et al. Intermediate Term Experience with Proximal Urethral Polypropylene Slings for Complex Stress Urinary Incontinence. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Level of evidence.
331 NCT00012740. A Casefinding and Referral System for Older Veterans Within Primary Care. 2001. Not eligible exposure.
332 NCT00064662. Randomized Clinical Trial of Burch vs Sling Procedures for Women With Stress Urinary Incontinence. 2006. Not eligible exposure.
333 NCT00075114. Prevent Inability To Control Urination. 2006. Not eligible exposure.
334 NCT00090584. Behavior Enhances Drug Reduction of Incontinence (BE-DRI). 2006. Not eligible exposure.
335 NCT00091988. Program to Reduce Incontinence by Diet and Exercise (PRIDE). 2007. Not eligible exposure.
336 NCT00124904. Biofeedback for Fecal Incontinence. 2006. Not eligible exposure.
337 NCT00127257. Biofeedback for Dyssynergic Constipation. 2006. Not eligible exposure.
338 NCT00127270. Using Behavioral Therapy in Combination With Darifenacin for Symptoms of Overactive Bladder. 2006. Not eligible exposure.
339 NCT00137397. A Study to Measure the Effect of Tolterodine Extended Release on the Thickness of the Bladder Wall in Patients With Overactive Bladder. 2006. Not eligible exposure.
340 NCT00138749. An 8 Week Study Looking At The Efficacy, Toleration And Safety Of SS-RBX For Stress Urinary Incontinence. 2006. Not eligible exposure.
341 NCT00139724. Evaluate Efficacy and Safety Of Tolterodine Extended Release Capsule Compared With Tolterodine Immediate Release Tablet. 2006. Not eligible exposure.
342 NCT00141128. Evaluation Of A Novel Methodology In The Assessment Of Urethral Function Using SS-RBX. Not eligible exposure.
343 NCT00143377. Study to Determine The Effectiveness Of Detrusitol In Patients Diagnosed With OAB. 2005. Not eligible exposure.
344 NCT00143481. Effect of Detrol LA on Overactive Bladder Symptoms, Sexual Quality of Life and Sexual Function in Women. Not eligible exposure.
345 NCT00147654. Effect and Safety Of Detrol LA In Men With Overactive Bladder Symptoms With Or Without Bladder Outlet Obstruction. Not eligible exposure.
346 NCT00170755. A Long-Term Safety, Tolerability and Efficacy Study of Darifenacin in Adult Patients With Overactive Bladder. 2005. Not eligible exposure.
347 NCT00171145. A 12-Week Study to Evaluate the Efficacy of Darifenacin to Increase the Warning Time in Patients With Overactive Bladder. 2004. Not eligible exposure.
348 NCT00174798. MILADY: A Randomized, Placebo-Controlled Safety and Efficacy Trial of SSR240600C in Treatment of Overactive Bladder or Urge Urinary Incontinence. Not eligible exposure.
349 NCT00178191. Randomized Trial for Botox Urinary Incontinence. 2008. Not eligible exposure.
350 NCT00178334. Screening for Urinary Incontinence by Primary Care Providers. 2006. Not eligible exposure.
351 NCT00190567. Biomechanical Effects of Duloxetine on Bladder and Sphincter Muscle Function in Women in Pure Genuine Stress Incontinence. 2006. Not eligible exposure.
352 NCT00190606. Efficacy and Safety of Duloxetine, Placebo and Pelvic Floor Muscle Training in Subjects With Stress Urinary Incontinence. 2006. Not eligible exposure.
353 NCT00190619. Efficacy and Safety of Duloxetine. 2006. Not eligible exposure.
354 NCT00190632. To Evaluate the Safety in Patients Taking Duloxetine for Stress Urinary Incontinence. 2006. Not eligible exposure.
355 NCT00190645. To Evaluate the Safety of Duloxetine in Patients With Stress Urinary Incontinence. 2006. Not eligible exposure.
356 NCT00190814. Effectiveness and Safety of Duloxetine in Women Experiencing Urinary Leakage Due to Physical Stress and Urge. 2006. Not eligible exposure.
357 NCT00190827. Effectiveness of Duloxetine in the Treatment of Stress Urinary Incontinence(Uncontrolled Leakage of Urine). 2006. Not eligible exposure.
358 NCT00190853. Biomechanical and Electrophysiological Effects of Duloxetine in the Treatment of Women With Urinary Stress Incontinence. 2006. Not eligible exposure.
359 NCT00190905. Safety and Effectiveness Study of Duloxetine HCl in Women of Different Backgrounds With Stress Urinary Incontinence Who May Also Have Other Various Medical Conditions. 2005. Not eligible exposure.
360 NCT00190996. Evaluate Safety and Efficacy of Duloxetine in Predominant Stress Urinary Incontinence. 2006. Not eligible exposure.
361 NCT00191087. Duloxetine in the Treatment of Stress Urinary Incontinence. 2006. Not eligible exposure.
362 NCT00191204. Open Label Phase III Duloxetine Study for Stress Urinary Incontinence. 2006. Not eligible exposure.
363 NCT00196404. Study to Evaluate the Safety and Efficacy of DR-3001 Versus Placebo in Women With Overactive Bladder. 2006. Not eligible exposure.
364 NCT00196521. A Clinical Evaluation of the Tension-Free Vaginal Tape Obturator System For Treatment of Stress Urinary Incontinence (Urinary Leakage). 2007. Not eligible exposure.
365 NCT00197314. Effectiveness of Circular Muscle Exercise (Paula Method) Versus Kegel Exercise for Urinary Stress Incontinence. 2006. Not eligible exposure.
366 NCT00212264. Conservative Treatment of Postprostatectomy Incontinence. 2009. Not eligible exposure.
367 NCT00213317. Effect of Lumbo-sacral Magnetic Stimulation on Colonic Motility. 2008. Not eligible exposure.
368 NCT00223106. Treatment for Stress and Mixed Urinary Incontinence and Vaginal Vault Prolapse. Not eligible exposure.
369 NCT00223821. Enhancing Conservative Treatment for Urge Incontinence. 2009. Not eligible exposure.
370 NCT00224146. Transdermal (TDS) Oxybutynin (Oxytrol(r)) in Overactive Bladder. Not eligible exposure.
371 NCT00230360. Diagnosis of Functional Defecation Disorders in Childhood. 2006. Not eligible exposure.
372 NCT00230789. Effect Of Detrol LA With Behavioral Intervention In Overactive Bladder Subjects Dissatisfied With Recent OAB Medication. Not eligible exposure.
373 NCT00231790. A Placebo-Controlled Study of MK0634 in Patients With Overactive Bladder. Not eligible exposure.
374 NCT00234754. Trans-Obturator Tape vs. Trans-Vaginal Tape for Stress Urinary Incontinence in Women. 2009. Not eligible exposure.
375 NCT00238680. Programmable Timer in the Bladder Rehabilitation Treatment of OAB. 2007. Not eligible exposure.
376 NCT00239824. Pelvic Floor Muscle Training to Treat Urinary Incontinence After Radical Prostatectomy. 2008. Not eligible exposure.
377 NCT00244296. To Determine How Effective Duloxetine is in Treating Women 65 Years and Older With Symptoms of Stress Urinary Incontinence, or With a Combination of Stress Urinary Incontinence and Urge Urinary Incontinence Symptoms. 2007. Not eligible exposure.
378 NCT00255372. To Determine the Effect of Forlax® Treatment in Children With Chronic Constipation Who May Also Suffer From Soiling/Faecal Incontinence. Not eligible exposure.
379 NCT00269724. A Study to Evaluate the Safety and Efficacy of OROS® Oxybutynin Chloride for the Treatment of Urge Urinary Incontinence. 1997. Not eligible exposure.
380 NCT00269750. A Study Comparing the Efficacy and Safety of OROS® Oxybutynin to That of Ditropan® (Immediate-release Oxybutynin) for the Treatment of Patients With Urge or Mixed Urinary Incontinence. 1997. Not eligible exposure.
381 NCT00270998. ATLAS: Ambulatory Treatments for Leakage Associated With Stress. 2008. Not eligible exposure.
382 NCT00271037. Colpocleisis for Advanced Pelvic Organ Prolapse. 2007. Not eligible exposure.
383 NCT00282490. Surface Nerve Stimulation Treatment for OAB in Children. 2008. Not eligible exposure.
384 NCT00282932. Detrol LA In Men With Overactive Bladder. Not eligible exposure.
385 NCT00286520. Treatment of Fecal Incontinence and Constipation in Patients With Spinal Cord Injury. 2005. Not eligible exposure.
386 NCT00290563. A Multicenter, Double-Blind, Randomized, Placebo-Controlled, Phase II Study of MK0594 in Patients With Overactive Bladder. Not eligible exposure.
387 NCT00293839. Efficacy and Tolerability of DITROPAN® XL (Oxybutynin Chloride) Versus DETROL® LA (Tolterodine Tartrate) in Treatment of Overactive Bladder. 2002. Not eligible exposure.
388 NCT00304499. Efficacy and Safety of OROS Oybutynin and TTS Oxybutynin in Middle-Aged and Elderly Women With Urinary Incontinence. 1996. Not eligible exposure.
389 NCT00307775. Vaginal Estrogen for the Treatment of Faecal Incontinence in Women. 2007. Not eligible exposure.
390 NCT00308009. Comparison of the Result of TVT Performed at the Time of Prolapse Surgery or 3 Months After. 2007. Not eligible exposure.
391 NCT00333112. A Study to Evaluate Solifenacin Succinate in Combination With Tamsulosin for the Treatment of Residual Overactive Bladder Symptoms (OAB) in Men. 2007. Not eligible exposure.
392 NCT00337090. A Study of YM178 in Patients With Symptomatic Overactive Bladder (DRAGON). 2007. Not eligible exposure.
393 NCT00337558. A Study of Solifenacin With Bladder Training Versus Solifenacin Alone in Patients With Overactive Bladder (SOLAR). 2007. Not eligible exposure.
394 NCT00350636. A Comparison of a New Drug to Treat Overactive Bladder vs. Placebo. 2007. Not eligible exposure.
395 NCT00368706. A Double-Blind, Paralleled Study Comparing Efficacy/Safety of Solifenacin to Tolterodine in Overactive Bladder Patients. 2008. Not eligible exposure.
396 NCT00376298. 2029. Urology Database to Evaluate Clinical Information and Improve Patient Care. Not eligible exposure.
397 NCT00392210. Assessment of Two Postoperative Techniques Used to Predict Voiding Efficiency After Gynecologic Surgery. 2009. Not eligible exposure.
398 NCT00448175. Overactive Bladder Innovative Therapy Trial (OrBIT). 2008. Not eligible exposure.
399 NCT00463554. TVT-SECUR A Pilot Study for the Treatment of Stress Urinary Incontinence. 2007. Not eligible exposure.
400 NCT00475358. Efficacy and Safety Stress Urinary Incontinence Study. 2005. Not eligible exposure.
401 NCT00475397. Duloxetine Stress Urinary Incontinence Efficacy and Safety Study. 2004. Not eligible exposure.
402 NCT00475696. Urge Incontinence Bladder Overactivity Study. 2005. Not eligible exposure.
403 NCT00475839. Study Comparing Tension-Free Vaginal Tape With the Monarc Procedure for Stress Urinary Incontinence. 2007. Not eligible exposure.
404 NCT00506116. Promoting Effective Recovery From Labor Urinary Incontinence (PERL). 2006. Not eligible exposure.
405 NCT00506766. Promoting Self Care to Prevent Urinary Incontinence (UI): A Four-Year Follow-up. 2006. Not eligible exposure.
406 NCT00525291. Triple Target Treatment (3T) Which Combines Stimulation With Amplitude Modulated Middle Frequency (AM-MF), Electromyography (EMG)-Triggered Stimulation and EMG-Biofeedback Compared With EMG-Biofeedback in Anal Incontinence. 2008. Not eligible exposure.
407 NCT00535301. Anatomic and Visceral Outcomes of Anterior Colporrhaphy Versus Graft Reinforced Anterior Prolapse Repair: a Randomized Controlled Trial. 2008. Not eligible exposure.
408 NCT00564226. SSR240600C Treatment in Women With Overactive Bladder. 2009. Not eligible exposure.
409 NCT00565838. Quality-of-Life Outcomes After Autologous Fascial Sling and TVT: a Prospective Randomized Trial. 2007. Not eligible exposure.
410 NCT00576004. Pelvic Organ Prolapse Repair With or Without Concomitant Burch Colposuspension in Patients With Urinary Incontinence. 2006. Not eligible exposure.
411 NCT00603343. Propiverine in Children Suffering From Non-Neurogenic Overactive Bladder and Urinary Incontinence. 2006. Not eligible exposure.
412 NCT00604838. Pivotal Study of the Al-Sense Study Protocol. 2006. Not eligible exposure.
413 NCT00658944. Predictive Objective Parameters for Outcome of the Treatment of Stress Urinary Incontinence. 2008. Not eligible exposure.
414 NCT00662207. Two Devices for Reflex Voiding Following Spinal Cord Injury. 2009. Not eligible exposure.
415 NCT00662909. Study to Test the Efficacy and Safety of the Beta-3 Agonist YM178 in Patients With Symptoms of Overactive Bladder. 2009. Not eligible exposure.
416 NCT00688298. Post Market Clinical Study to Evaluate a Mid-Urethral Vaginal Tape Procedure With a Pre-Pubic Delivery Approach, for the Treatment of Stress Urinary Incontinence. 2008. Not eligible exposure.
417 NCT00689104. Study to Test the Efficacy and Safety of the Beta-3 Agonist YM178 in Subjects With Symptoms of Overactive Bladder. 2009. Not eligible exposure.
418 NCT00691093. Study In Patients With Overactive Bladder Treated With Toviaz® After Failure Of Previous Therapy. 2009. Not eligible exposure.
419 NCT00699049. A Study Comparing the Efficacy of an Alpha Blocker Versus an Alpha Blocker Plus Solifenacin in Men With Overactive Bladder. 2010. Not eligible exposure.
420 NCT00740428. Pelvic Floor Exercises During Gestation in the Prevention of Urinary Incontinence and Pelvic Floor Muscle Dysfunction. 2009. Not eligible exposure.
421 NCT00742833. A Phase II Study of KUC-7483 in Patients With Overactive Bladder. Not eligible exposure.
422 NCT00747370. Dynamic MRI of the Behaviour of Female Pelvic Floor. 2008. Not eligible exposure.
423 NCT00749632. A Study of Oxybutynin for the Treatment of Urge Urinary Incontinence. 2008. Not eligible exposure.
424 NCT00765622. Assessment of Pelvic Floor Function in Elderly. 2007. Not eligible exposure.
425 NCT00782990. A 3 Year Follow-up Prospective Open Randomized Trial of TVT Versus Colposuspension for Primary Stress Incontinence. 2007. Not eligible exposure.
426 NCT00795925. Dose-Escalating Study of Propiverine Hydrochloride in Children Suffering From Overactive Bladder. 2005. Not eligible exposure.
427 NCT00801203. A Study to Evaluate the Effectiveness of the Induced Reflex Cough Test Plus Urodynamics to Identify Stress Urinary Incontinence in Female Subjects With a History of Stress Urinary Incontinence. 2009. Not eligible exposure.
428 NCT00843908. Tension Free Vaginal Tape (TVT) Versus the Miniarc Sling. 2009. Not eligible exposure.
429 NCT00850590. Study of Escalating Doses of NRL001 Given in Slow-release Rectal Suppositories of Different Weights. Not eligible exposure.
430 NCT00850733. 516-BOTOX Urinary Incontinence Detrusor. 2009. Not eligible exposure.
431 NCT00857467. Study to Investigate Safety and Response to 1 or 2 g Rectal Suppositories Containing 5 or 10 mg NRL001. Not eligible exposure.
432 NCT00880880. Improving Women’s Health by Using an Electronic Pelvic Floor Questionnaire. Not eligible exposure.
433 NCT00893607. Effect of Single Doses of 10 mg NRL001 Applied as a Suppository to the Anal Canal or Rectum. 2007. Not eligible exposure.
434 NCT00904618. Safety and Efficacy Study on the Implantation of the Tension-Free Vaginal Tape (TVT-Secur) Under Local Anesthesia. 2009. Not eligible exposure.
435 NCT00906607. Prevalence of Urinary Incontinence in Different Age Categories. 2008. Not eligible exposure.
436 NCT00906854. Urinary Incontinence and Practice of Physical Exercises. 2008. Not eligible exposure.
437 NCT00911235. The Effect Of Fluconazole On Pharmacokinetics Of Fesoterodine In Healthy Subjects. 2009. Not eligible exposure.
438 NCT00912964. A Study to Test the Efficacy and Safety of the Beta-3 Agonist YM178 in Subjects With Symptoms of Overactive Bladder. 2010. Not eligible exposure.
439 NCT00927849. Idiopathic Hypertensive Anal Canal: a Place of Internal Sphincterotomy. 2008. Not eligible exposure.
440 NCT00939432. Taboo Perception of Incontinence, Depression and Cancer. 2007. Not eligible exposure.
441 NCT00942370. Electromyographic (EMG) and Mechanomyographic (MMG) Comparison. 2009. Not eligible exposure.
442 NCT00965926. A Study to Investigate the Food Effect on the Pharmacokinetics of YM178 in Healthy, Non-elderly Volunteers. 2009. Not eligible exposure.
443 NCT00972998. Study to Examine the Effect of Coated Phenylephrine Suppositories on Anal Pressure in Healthy Subjects. 2009. Not eligible exposure.
444 NCT01042275. Patient-reported Outcome After Sling Insertion Using the Incontinence Outcome Questionnaire (IOQ). 2010. Not eligible exposure.
445 NCT01042821. Treatment of Anal Fistulas Advancement Flap. 2008. Not eligible exposure.
446 NCT01056666. Conveen Optima Urisheaths With Collecting Bags Versus Absorbents on Men Suffering of Moderate to Severe Urinary Incontinence. 2009. Not eligible exposure.
447 NCT01057550. Randomised Controlled Trial Comparing Tension-Free Vaginal Tape (TVT), Pelvicol & Autologous Slings for Stress Urinary Incontinence(SUI). 2006. Not eligible exposure.
448 NCT01091727. Intravesical Injection of Botulinum Toxin A Versus Saline for Neurogenic Detrusor Overactivity. 2009. Not eligible exposure.
449 NCT01108367. Transient Urinary Incontinence After Holmium Laser Enucleation of the Prostate (HoLEP). Not eligible exposure.
450 Nguyen MT, Pavlock CL, Zderic SA, et al. Overnight catheter drainage in children with poorly compliant bladders improves post-obstructive diuresis and urinary incontinence. Journal of Urology. 2005;174(4 II):1633-6. Level of evidence. [pmid: 16148670].
451 Nill TG, Peller PA, Kropp KA. Management of urinary incontinence by bladder tube urethral lengthening and submucosal reimplantation. Journal of Urology. 1990;144(2 II):559-61. Level of evidence. [pmid: 2374240].
452 Nilsson CG. The tensionfree vaginal tape procedure (TVT) for treatment of female urinary incontinence. A minimal invasive surgical procedure. Acta Obstetricia et Gynecologica Scandinavica, Supplement. 1998;77(168):34-7. Level of evidence. [pmid: 9744788].
453 NTR602. Primary prevention of bed-wetting: the effectiveness of simple interventions by the parents. Not eligible exposure.
454 NTR778. Performance of the miniaturo?-I system for treatment of overactive bladder. Not eligible exposure.
455 NTR829. Effects of introducing a specialized nurse in the care of community-dwelling women suffering from urinary incontinence. Not eligible exposure.
456 NTR1131. Optimal Stimulation Rates in Sacral Neuromodulation Therapy. Not eligible exposure.
457 NTR1141. A multi-centre randomised comparison of the effectiveness and safety of TVT-O and TVT-S. Not eligible exposure.
458 Ocampo MS Jr, Diokno AC, Ibrahim IA, et al. Group Session Teaching of Behavioral Modification Program (BMP) for Urinary Incontinence (UI): A Randomized, Controlled Trial among Incontinent Women. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Level of evidence.
459 O’Connor RC, Nanigian DK, Lyon MB, et al. Early Outcomes of Mid-Urethral Slings for Female Stress Urinary Incontinence Stratified by Valsalva Leak Point Pressure. Paper presented at: 2006 Annual Meeting of the American Urological Association (AUA 2006). Atlanta, Georgia (USA). 20–25 May 2006. Level of evidence.
460 Oliveira LM, Girao MJBC, Sartori MGF, et al. Comparison of Retro Pubic Tvt, Pre Pubic Tvt and Tvt Transobturator in Surgical Treatment of Women with Stress Urinary Incontinence. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
461 Ortiz OC. Sling Type Surgery in Stress Urinary Incontinence Treatment. Paper presented at: XVIII FIGO World Congress of Gynecology and Obstetrics (FIGO 2006), Kuala Lumpur Convention Centre (KLCC). Kuala Lumpur (Malaysia). 5–10 Nov 2006. Level of evidence.
462 Ostergard DR. New approaches to the treatment of stress urinary incontinence. Advanced Studies in Medicine. 2004;4(2 A). Level of evidence.
463 Oyama IA, Steinberg AC, Feloney MP. Advanced procedures for urinary incontinence. Journal of Pelvic Medicine and Surgery. 2004;10(6):289-304. Level of evidence.
464 Pace G, Paradiso Galatioto G, Costa AM, et al. Treatment of urinary incontinence through functional electrical stimulation of the pelvic floor: Our experience. Trattamento dell’incontinenza urinaria mediante stimolazione elettrica funzionale del pavimento pelvico: La nostra esperienza. 2005;19(1 SUPPL):402-4. Level of evidence.
465 Palazzo A, Balsamo G, Carotenuto V, et al. Sparc technique in the treatment of stress urinary incontinence: Short- to medium-term follow-up. Tecnica Sparc nel trattamento della incontinenza urinaria da stress: Follow-up a breve e medio termine. 2006;20(2):333-5. Level of evidence.
466 Panel L, de Tayrac R, Mares P. Pregnancy Following Surgical Treatment of Stress Urinary Incontinence using Vaginal Tapes. Results of a French National Survey. Paper presented at: 31st Annual Meeting of the International Urogynecological Association, Athens Hilton Hotel. Athens (Greece). 6–9 Sep 2006. Level of evidence.
467 Pansadoro V, Ferdinandi V, Acri GF, et al. The. AMS. 800 prosthesis in the treatment of urinary incontinence. Acta Chirurgica Italica. 1991;47(1):207-8. Level of evidence.
468 Paraiso MFR, Walters MD. Laparoscopic surgery for stress urinary incontinence and pelvic organ prolapse. Clinical Obstetrics and Gynecology. 2005;48(3):724-36. Level of evidence. [pmid: 16012239].
469 Parziani S, Catanzani A. The treatment of stress urinary incontinence through tension-free vaginal tape. Il trattamento dell’incontinenza urinaria da sforzo mediante tension-free vaginal tape. 2005;19(1 SUPPL):405-6. Level of evidence.
470 Payne CK. Epidemiology, pathophysiology, and evaluation of urinary incontinence and overactive bladder. Urology. 1998;51(2 SUPPL A):3-10. Level of evidence. [pmid: 9495728].
471 Pelosi MA III, Pelosi MA II. Laparoscopic assessment of the sparc sling system for treatment of stress urinary incontinence. Paper presented at: 31st Annual Meeting of the International Congress of Gynecologic Endoscopy. Miami Beach, FL (USA). 20–24 Nov 2002. (World Meeting Number 000 6527). Level of evidence.
472 Penning-van Beest FJA, Sturkenboom M, Herings RMC. Treatment of urinary incontinence in daily practice does not comply with the guidelines. Paper presented at: International Soc. for Pharmacoeconomics and Outcomes Research 6th Annual European Congress. Barcelona (Spain). 9–11 Nov 2003. (World Meeting Number 000 7153). Level of evidence.
473 Pennisi M, Grasso-Leanza F, Panella P, et al. Rehabilitative therapy in the treatment of urinary stress incontinence. Our experience on 121 patients. LA TERAPIA RIABILITATIVA NEL TRATTAMENTO DELL’INCONTINENZA URINARIA FEMMINILE. LA NOSTRA ESPERIENZA SU 121 PAZIENTI. 1994;46(4):245-9. Level of evidence.
474 Phull H, Salkini M, Escobar C, et al. The role of angiotensin II in stress urinary incontinence: A rat model. Neurourology and Urodynamics. 2007;26(1):81-8. Level of evidence. [pmid: 17029249].
475 Pickens RB, Klein FA, Doggweiler R. Short Term Efficacy of the MiniArcTM Single Incision Sling System for the Treatment of Stress Urinary Incontinence. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
476 Pifarotti P, Spennacchio M, Gattei U, et al. A randomized prospective comparison of TVT and endopelvic fascia plication in the treatment of occult stress urinary incontinence in patients with genital prolapse: Preliminary data. Urogynaecologia International Journal. 2001;15(1 SUPPL):55-7. Level of evidence.
477 Pigne A. Effort-related urinary incontinence should not be dealt with surgically. LES INCONTINENCES URINAIRES D’EFFORT A NE PAS OPERER. 1993;88(3):127-8. Level of evidence.
478 Pike JG, Berardinucci G, Hamburger B, et al. The surgical management of urinary incontinence in myelodysplastic children. Journal of Pediatric Surgery. 1991;26(4):466-71. Level of evidence. [pmid: 2056409].
479 Pinggera GM, Spranger R, Strasser H, et al. Assessment of Pelvic Neuropathy in Female Stress Urinary Incontinence. Paper presented at: 2006 Annual Meeting of the American Urological Association (AUA 2006). Atlanta, Georgia (USA). 20–25 May 2006. Level of evidence.
480 Politi PL, Sandri SD, Fanciullacci F, et al. Perineal electrical stimulation in the treatment of urinary incontinence due to detrusor instability. LA STIMOLAZIONE ELETTICA PERINEALE NEL TRATTAMENTO DELLA INCONTINENZA URINARIA DA INSTABILITA DETRUSORIALE. 1992;6(SUPPL 4):417-8. Level of evidence.
481 Preyer O, Laml T, Umek W, et al. Peripheral Tibial Neurostimulation (PTNS) (Urgent PC ) versus Tolterodine (Detrusitol ) in the Treatment of Women with Urge Urinary Incontinence and Urge Symptoms. Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Level of evidence.
482 Puggioni GF, Deriu P, Corona R, et al. Treatment of stress urinary incontinence through suburethral sling: Comparison of two tension-free procedures. Trattamento dell’incontinenza urinaria da sforzo mediante sling sottouretrale: Due procedure tension-free a confronto. 2007;21(2):7-9. Level of evidence.
483 Quellari P, Viganò R, Gandini L, et al. Retropubic colpocystourethropexy according to Burch and tension-free vaginal tape in the treatment of stress urinary incontinence. Colposospensione retropubica secondo Burch e tension free vaginal tape nella terapia dell’incontinenza urinaria da sforzo. 2001;15(1 SUPPL):163-5. Level of evidence.
484 Rahman NU, Minor TX, Deng D, et al. Combined external urethral bulking and artificial urinary sphincter for urethral atrophy and stress urinary incontinence. BJU International. 2005;95(6):824-6. Level of evidence. [pmid: 15794791].
485 Randone DF, Carone R, Manassero A, et al. Tension-Free Vaginal Tape in the treatment of genuine stress urinary incontinence in women: Own experience. Tension Free Vaginal Tape (T.V.T.) nel trattamento dell’incontinenza urinaria da sforzo genuina nella donna: Nostra esperienza. 2001;15(1 SUPPL):66-7. Level of evidence.
486 Rautenstrauch J. Urinary incontinence: How to get the bladder under control again. Harninkontinenz: So bringen sie die blase wieder unter kontrolle. 1999;141(41):16. Level of evidence.
487 Rechberger T, Jankiewicz K, Futyma K, et al. Clinical effectiveness of retropubic (IVS-02) and transobturator (IVS-04) slings in the treatment of female stress urinary incontinence - a semi-randomized trial on 398 patients. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
488 Rechberger T, Postawski K, Jakowicki JA, et al. Role of fascial collagen in stress urinary incontinence. American Journal of Obstetrics and Gynecology. 1998;179(6 I):1511-4. Level of evidence. [pmid: 9855589].
489 Rehder P, Bektic J, Bartsch G, et al. A Transobturator Approach for a Sling to Treat Male Urinary Incontinence. Paper presented at: 2006 Annual Meeting of the American Urological Association (AUA 2006). Atlanta, Georgia (USA). 20–25 May 2006. Level of evidence.
490 Richter H. A Randomized Trial of Pessary vs. Behavioral Therapy vs. Combined Therapy for Treatment of Stress Urinary Incontinence. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
491 Richter H, Nygaard I, Huang L, et al. Characteristics of Obese, Overweight and Normal (Healthy) Weight Women Seeking Surgical Treatment for Stress Urinary Incontinence. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
492 Rink RC, Adams MC, Keating MA. The flip-flap technique to lengthen the urethra (Salle procedure) for treatment of neurogenic urinary incontinence. Journal of Urology. 1994;152(2 II):799-802. Level of evidence. [pmid: 8022018].
493 Roa J, Martinez J. Importance of Midurethral Placement of the Safyre Tape (TOT) for Treatment of different Types of Stress Urinary Incontinence. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
494 Rodrigues A, Ferreira A, Abreu A, et al. Comparative Study of Retropubic and Transobturator Approaches for the Treatment of Female Urinary Incontinence. Paper presented at: 11th World Congress on Controversies in Obstetrics, Gynecology and Infertility (COGI 2008). Paris (France). 27–30 Nov 2008. Level of evidence.
495 Roh J, Han D, Lim D, et al. Midterm Data on Tension-Free Vaginal Tape Obturator Procedure for the Treatment of Stress Urinary Incontinence. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
496 Romero J, Ortiz M, Prieto L, et al. TOA adjustable mesh for surgical treatment of female stress urinary incontinence. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
497 Rota G, Ferrara R, Iovine MC, et al. Minimally invasive surgical treatment of stress urinary female incontinence. Our experience of 50 patients who underwent TOT. Trattamento chirurgico mini-invasivo della IUS femminile. Nostra esperienza su 50 pazienti sottoposte a TOT. 2005;19(1 SUPPL):213-5. Level of evidence.
498 Rouprêt M. Prostate cancer, urinary incontinence, testicular cancer. Cancer de la prostate, incontinence urinaire, cancer du testicule. 2008;18(1). Level of evidence.
499 Rowe PJ. New system for measurement of pelvic floor muscle strength in urinary incontinence. Paper presented at: 12th International Congress of the World Federation for Physical Therapy. Washington DC (USA). 25–30 Jun 1996. (World Meeting Number 962 5007). Level of evidence.
500 Rowe PJ, Booth J, Salter PM. New system for the measurement of pelvic floor muscle strength in urinary incontinence. Paper presented at: 12th International Congress of the World Confederation for Physical Therapists. Washington, DC (USA). 20–25 Jun 1995. (World Meeting Number 952 0043). Level of evidence.
501 Ruffion A, Dembele D, N’Goi C, et al. Sacral root neuromodulation for the treatment of urinary incontinence reported to detrusor hyperactivity. Traitement de l’incontinence urinaire secondaire à une hyperactivité vésicale par neuromodulation sacrée. 2003;49(2–3 II):377-82. Level of evidence.
502 Ruthmann O, Karcz W, Goldschmidboeing F, et al. German Artificial Sphincter Systems -GASS III:The first generation of a remote-controlled artificial sphincter prosthesis for the therapy of high-grade fecal- and urinary - incontinence. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
503 Rutman M, Itano N, Deng DY, et al. Long Term Durability of the Distal Urethral Polypropylene Sling (Dups) Procedure for Stress Urinary Incontinence: Minimum 5-Year Follow-Up of Surgical Outcome and Satisfaction Determined by Patient Reported Questionnaires. Paper presented at: 2006 Annual Meeting of the American Urological Association (AUA 2006). Atlanta, Georgia (USA). 20–25 May 2006. Level of evidence.
504 Salle JLP, De Fraga JCS, Amarante A, et al. Urethral lengthening with anterior bladder wall flap for urinary incontinence: A new approach. Journal of Urology. 1994;152(2 II):803-6. Level of evidence. [pmid: 8022019].
505 Saltel E, Hajek D, Herschorn S. Periurethral Collections Following Hyaluronic Acid/Dextranomer (Zuidex A@@u®@) Injection for Female Stress Urinary Incontinence. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Level of evidence.
506 Salvatore S, Serati M, Zanfra M, et al. Efficacy of Antimuscarinics in Women with Anterior Vaginal Wall Prolapse: Is it the Same?. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
507 Samouelian V, Cosson M, Fernandez H, et al. Is Prepubic-Tvt Effective for the Surgical Treatment of Female Stress Urinary Incontinence?. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
508 Samsioe GN. Urinary Incontinence: New Insights into Patho-Physiology Yield Novel Treatment Options. Paper presented at: XVIII FIGO World Congress of Gynecology and Obstetrics (FIGO 2006), Kuala Lumpur Convention Centre (KLCC). Kuala Lumpur (Malaysia). 5–10 Nov 2006. Level of evidence.
509 Sand PK, Kelleher CJ, Dahl N. Nocturia in a Large Community Population Treated with Transdermal Oxybutynin. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
510 Sand PK, Kelleher CJ, Pizzi L, et al. Effect of Treatment for Overactive Bladder on Work Productivity. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
511 Sarma AV, Subak LL, Lin F, et al. Prevalence and Risk Factors for Female and Male Urinary Incontinence: Results from Nhanes 2001–2002. Paper presented at: 2006 Annual Meeting of the American Urological Association (AUA 2006). Atlanta, Georgia (USA). 20–25 May 2006. Level of evidence.
512 Sarmento R, GonAscalves P, Matos I, et al. Treatment of female stress urinary incontinence with three different tapes - a four-year experience. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
513 Sarnelli G. Female stress urinary incontinence. Echographic diagnosis. Incontinenza urinaria femminile da sforzo. Diagnostica ecografica. 2007;21(2):133-7. Level of evidence.
514 Sarnelli G. Female stress urinary incontinence. Ultrasound diagnosis. Incontinenza urinaria femminile da sforzo. Diagnostica ecografica. 2008;22(2):13-7. Level of evidence.
515 Sassani P, Aboseif S, Franke E, et al. Treatment of Moderate to Severe Female Stress Urinary Incontinence with the Adjustable Continence Therapy Device (Act) after Failed Surgical Repair. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
516 Savov O, Rall HE. Duloxetin - The First Evidence-Based Pharmacotherapy Agent for the Therapy of Stress Urinary Incontinence (SUI). Paper presented at: 2006 International Disease Management Symposium on Modern Pharmacotherapy in Urology. Hotel Admiral, Resort Golden Sands, Varna (Bulgaria). 4–7 May 2006. Level of evidence.
517 Schettini M, Fortunato P, Spina F, et al. The treatment of urinary incontinence from sphincteric damage with artificial sphincter AMS 800. TRATTAMENTO DELL’INCONTINENZA URINARIA DA DANNO SFINTERICO CON LO SFINTERE ARTIFICIALE AMS 800. 1992;6(SUPPL 6):181-4. Level of evidence.
518 Schettini M, Greco U, Savoia G. Treatment of female urinary incontinence with in-fast sling. Trattamento dell’incontinenza urinaria femminile con “in-fast” sling. 2001;15(1 SUPPL):180-2. Level of evidence.
519 Schiavini J, de Resende J Junior, Dornas M, et al. Surgical Implantation of the Periurethral Constrictor and Its Activation for the Treatment of the Male Urinary Incontinence. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
520 Schurch B, Denys P, Barron RB, et al. Botulinum Toxin a (BoNTA) Treatment in Patients with Neurogenic Urinary Incontinence Shows Significant Improvements: A Quality of Life Questionnaire. Paper presented at: 9th Congress of the European Federation of Neurological Societies (EFNS 2005), Congress Centre OMMA of the Megaron. Athens (Greece). 17–20 Sep 2005. Level of evidence.
521 Segal JL, Vassallo BJ, Kleeman SD, et al. Efficacy of the tension free vaginal tape in the treatment of five sub-types of stress urinary incontinence. Paper presented at: 23rd Annual Meeting of the American Urogynecologic Society. San Fracisco, CA (USA). 17–19 Oct 2002. (World Meeting Number 000 6467). Level of evidence.
522 Seim A, Hunskaar S. Female urinary incontinence - The role of the general practitioner. Acta Obstetricia et Gynecologica Scandinavica. 2000;79(12):1046-51. Level of evidence. [pmid: 11130085].
523 Sender H, Green J. Comparison of Transobturator and Transabdominal Tapes for Surgical Treatment of Female Stress Urinary Incontinence. Paper presented at: 21st Annual Congress of the European Association of Urology (EAU 2006), Palais des Congres. Paris (France). 5–8 Apr 2006. Level of evidence.
524 Shafik A. Stress urinary incontinence: New concept of pathogenesis and treatment by pudendal canal decompression. 2004;539 A:415-40. Level of evidence.
525 Shengqi L, Xunping Z, Jie Z. Surgical Treatment of Female Stress Urinary Incontinence with Transobturator Vaginal Tape inside-Out: Long Term Results (Report of 159 Cases). Paper presented at: 26th World Congress of Endourology (WCE 26), Shanghai International Convention Center (SICC). Shanghai (China). 30 Nov–3 Dec 2008. Level of evidence.
526 Shim K, Seo Y, Heo J. The Influence of Surgical Treatment on Sexual Function in Female Patients with Stress Urinary Incontinence. Paper presented at: 12th World Congress of the International Society for Sexual Medicine (ISSM 2006). Hotel Heliopolis, Cairo (Egypt). 17–21 Sep 2006. Level of evidence.
527 Siegal DL, Balsam A, Bottum C, et al. Can we talk? Educating health care providers and the public about urinary incontinence. The Massachusetts educate program (Educational demonstration of urinary continence assessment and treatment for the elderly). Paper presented at: American Public Health Association 122nd Annual Meeting and Exhibition: Public Health and Diversity--Opportunities for Equity. Washington DC (USA). 30 Oct–3 Nov 1994. (World Meeting Number 944 0901). Level of evidence.
528 Siroky MB. Current treatment options for stress urinary incontinence. Advanced Studies in Medicine. 2003;3(8 E). Level of evidence.
529 Sivaslioglu A, Dolen I. Long-Term Results of the Paraurethral Tension-Free Vaginal Approach for the Treatment of Stress Urinary Incontinence. Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Level of evidence.
530 Sonksen J, Bonde B, Laessoe L, et al. Transcutaneous Mechanical Nerve Stimulation (TMNS) using Perineal Vibration - A Novel Method for the Treatment of Female Stress Urinary Incontinence. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
531 Sotiropoulou M, Athanasiou S, Vlachos G, et al. Is Improvement of Urinary Incontinence after Duloxetine Treatment Associated to Mood and Anxiety Changes?. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
532 Sousa A, Uribarri C. Long term follow-up of the Male Readjustable Sling (Male Remeex System) for the surgical treatment of Male urinary incontinence. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
533 Souza SAF, Da Silva MM, Faintuch J, et al. Urinary Incontinence in Female Bariatric Candidates. Paper presented at: 2nd Congress of the IFSO European Chapter. Congress Palace, Lyon (France). 27–29 Apr 2006. Level of evidence.
534 Stanton SL. Indications and operative treatment of stress urinary incontinence. European Journal of Obstetrics Gynecology and Reproductive Biology. 1994;55(1):45-6. Level of evidence.
535 Starkman JS, Wolter CE, Scarpero HM, et al. Management of refractory urinary urge incontinence following urogynecological surgery with sacral neuromodulation. Neurourology and Urodynamics. 2007;26(1):29-35. Level of evidence. [pmid: 17083097].
536 Stefano U. Is Urinary Incontinence at Orgasm Really Related to Detrusor Overactivity? a Prospective Study to Assess Pathogenesis and Treatment. Paper presented at: 13th World Congress of Gynecological Endocrinology. Florence (Italy). 28 Feb–2 Mar 2008. Level of evidence.
537 Steffens J, Langen PH. Urinary incontinence of old men. MIKTIONSSTORUNGEN BEI MANNERN IM ALTER. 1998;22:215-8. +337. Level of evidence.
538 Stenberg Å. Transurethral endoscopic treatment of urinary stress incontinence in women. Materials and results in former and present agents. Acta Obstetricia et Gynecologica Scandinavica, Supplement. 1998;77(168):44-6. Level of evidence. [pmid: 9744790].
539 Stoffel JT, Lodowski C, Crivellaro S, et al. Preoperative Urodynamic Detrusor Instability Negatively Affects Quality of Life after Pubovaginal Sling in Patients with Mixed Urinary Incontinence. Paper presented at: 2006 Annual Meeting of the American Urological Association (AUA 2006). Atlanta, Georgia (USA). 20–25 May 2006. Level of evidence.
540 Strasser H, Marksteiner R, Margreiter E, et al. Basics of transurethral ultrasound guided stem cell therapy for urinary incontinence. Grundlagen der ultraschallgezielten transurethralen Stammzelltherapie der Harn-Inkontinenz. 2005;12(4):28-30. Level of evidence.
541 Strasser H, Marksteiner R, Margreiter E, et al. Transurethral Ultrasound Guided Stem Cell Therapy of Urinary Incontinence. Paper presented at: 21st Annual Congress of the European Association of Urology (EAU 2006), Palais des Congres. Paris (France). 5–8 Apr 2006. Level of evidence.
542 Strasser H, Mitterberger M, Marksteiner R, et al. Transurethral Ultrasonography Guided Injection of Autologous Myo- And Fibroblasts Versus Transurethral Endoscopic Injection of Collagen in Treatment of Urinary Incontinence in Women. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Level of evidence.
543 Summitt RL, Stovall TG, Bent AE, et al. Urinary incontinence: Correlation of history and brief office evaluation with multichannel urodynamic testing. American Journal of Obstetrics and Gynecology. 1992;166(6 I):1835-44. Level of evidence. [pmid: 1615993].
544 Sung LH, Noh CH, Chung JY, et al. The SPARC procedure for the treatment of female stress urinary incontinence in the elderly. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
545 Sung LH Sr, Park Jm Sr, Yu J Sr, et al. The Results of SPARC Procedure for Female Stress Urinary Incontinence Stratified by Preoperative Valsalva Leak Point Pressure. Paper presented at: 2008 Annual Meeting of the American Urological Association. Orlando, Florida (USA). 17–22 May 2008. Level of evidence.
546 Surbek D. Sling operations for the treatment of female stress urinary incontinence. Schlingenoperationen zur behandlung der weiblichen stressinkontinenz. 2006;46(1–2):68-71. Level of evidence.
547 Sutherland S, Aboseif S, Nash S, et al. Is Age a Predictor for Success with the Adjustable Continence Therapy (ActRG) System for Stress Urinary Incontinence?. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
548 Sylvain M. Surgical Treatment of Stress Urinary Incontinence using Tvt, Trans-Obturator Out-In and Trans-Obturator In-Out Techniques : What are the Results?. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
549 Szonyi G, Gatenby K, Khadra M, et al. SF-36 and quality of life in treatment of urinary incontinence. Paper presented at: 27th Annual Meeting of the International Continence Society. Yokohama (Japan). 23–26 Sep 1997. (World Meeting Number 973 0118). Level of evidence.
550 Tamanini T, Lebrao ML, Duarte YAO, et al. Analysis of the prevalence of and factors associated with urinary incontinence among elderly people - sabe study (health, wellbeing and aging). Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
551 Taurelle R. Urinary incontinence in women which should not be dealt with surgically. LES INCONTINENCES URINAIRES DE LA FEMME QU’IL NE FAUT PAS OPERER PRESENTATION. 1993;88(3):121-3. Level of evidence.
552 Taurelle R. Surgical treatment of urinary incontinence in women must be fully documented. LE TRAITEMENT CHIRURGICAL DE L’INCONTINENCE URINAIRE FEMININE DOIT ETRE PARFAITEMENT DOCUMENTE. 1993;88(3):125-6. Level of evidence.
553 ter Meulen PH, Berghmans LCM, Nieman FHM, et al. MacroplastiqueARG Implantation System for the treatment of urodynamic stress urinary incontinence caused by urethral hypermobility in adult women after non-successful conservative treatment: a randomized clinical trial. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
554 Thom DH. The epidemiology and evaluation of urinary incontinence. Advanced Studies in Medicine. 2004;4(2 A). Level of evidence.
555 Tibaek S. Effect of pelvic floor training program on female urinary incontinence. Paper presented at: 12th International Congress of the World Confederation for Physical Therapists. Washington, DC (USA). 20–25 Jun 1995. (World Meeting Number 952 0043). Level of evidence.
556 Tibaek S. Effect of a pelvic floor training program on female urinary incontinence. Paper presented at: 12th International Congress of the World Federation for Physical Therapy. Washington, DC (USA). 25–30 Jun 1996. (World Meeting Number 962 5007). Level of evidence.
557 Topuzovic C, Micic S. Stamey Bladder Neck Suspension and Nonoperative Management for the Treatment of Mixed Urinary Incontinence in Women - A Prospective Comparison and Long-Term Results. Paper presented at: 21st Annual Congress of the European Association of Urology (EAU 2006), Palais des Congres. Paris (France). 5–8 Apr 2006. Level of evidence.
558 Torrisi G, Leanza V, Vecchio M, et al. Perineal rehabilitation in the treatment of female urinary incontinence: Results and analysis of failure factors. La riabilitazione perineale nel trattamento dell’incontinenza urinaria femminile: Risultati ed analisi dei fattori di fallimento. 2005;19(1 SUPPL):281-5. Level of evidence.
559 Trabuco E, Klingele C, McGree M, et al. Pre and Post-Operative Predictors of Satisfaction Following Surgical Treatment of Stress Urinary Incontinence. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
560 Tremback-Ball A, Weber JD. Women&#39;s Perceived Urinary Incontinence Educational Needs. Paper presented at: 2008 Annual Conference and Exposition of the American Physical Therapy Association (PT 2008). San Antonio, Texas (USA). 11–14 Jun 2008. Level of evidence.
561 Trezza G, Rotondi M, Palmisano B, et al. Uterovaginal prolapse and occult urinary incontinence: A prospective randomized study on the necessity to associate reconstructive surgery and antiincontinence procedure. Prolasso utero-vaginale ed incontinenza urinaria occulta: Studio prospettico randomizzato sulla necessitá di associare chirurgia ricostruttiva e procedure antiincontinenza. 2001;15(1 SUPPL):152-4. Level of evidence.
562 Tries J. Protocol- and Therapist-Related Variables Affecting Outcomes of Behavioral Interventions for Urinary and Fecal Incontinence. Gastroenterology. 2004;126(1). Level of evidence.
563 Tsagaraki V, Markantonis S, Nikolaou S, et al. Exploring the Methods Used for the Diagnosis of Urinary Incontinence in Greece. The Dada Study. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
564 Tsarpalis D, Lagadas A, Balakitsas N, et al. The use of the Transobturator Tape (TOT) in the Treatment of Stress Urinary Incontinence. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
565 Turk Z. Methods of Physiotherapeutic Treatment of Urinary Incontinence. Paper presented at: XVIII FIGO World Congress of Gynecology and Obstetrics (FIGO 2006), Kuala Lumpur Convention Centre (KLCC). Kuala Lumpur (Malaysia). 5–10 Nov 2006. Level of evidence.
566 Turk Z. Treatment of women urinary incontinence. Paper presented at: XVII FIGO World Congress of Gynecology and Obstetrics. Santiago (Chile). 2–7 Nov 2003. (World Meeting Number 000 7240). Level of evidence.
567 Urban M, Heracek J, Novotny T, et al. ARGUS adjustable male sling - a new surgical method in the treatment of urinary incontinence in men. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
568 Vakili B, Chesson RR. Behavioral therapy for urinary incontinence and nonsurgical management of pelvic organ prolapse. Journal of Pelvic Medicine and Surgery. 2005;11(3):105-27. Level of evidence.
569 Valentim-Lourenco A, Marques J, Coelho A, et al. Quality of Life Analysis for Surgical Treatment Results of Stress and Mixed Urinary Incontinence. - a Prospective Observacional Study. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
570 Valiquette L, Paquin JM, Perreault JP, et al. Perineal retraining in urinary stress incontinence. LA REEDUCATION PERINEALE DANS L’INCONTINENCE URINAIRE D’EFFORT. 1991;45(9):816-21. Level of evidence.
571 Van Camp C. Surgical treatment of stress urinary incontinence in women under local anesthesia. Traitement chirurgical sous anesthesie locale de l’incontinence d’effort chez la femme. 1999;67(1):18-22. Level of evidence.
572 Van Kessel K, Reed S, Newton K, et al. The second stage of labor and stress urinary incontinence. American Journal of Obstetrics and Gynecology. 2001;184(7):1571-5. Level of evidence. [pmid: 11408883].
573 Vella M, Cardozo L. Urinary incontinence in the female patient. Practitioner. 2005;249(1670):345-56. Level of evidence. [pmid: 15902807].
574 Veticka J, Schraml J, Pavlik I, et al. Cizolirtine Citrate, An Effective Treatment for Urinary Incontinence Secondary to Overactive Bladder. Paper presented at: 21st Annual Congress of the European Association of Urology (EAU 2006), Palais des Congres. Paris (France). 5–8 Apr 2006. Level of evidence.
575 Vico MTC, Balazote AC, Laforga EdA, et al. TVT in the Treatment of Stress Urinary Incontinence: Intraoperative and Postoperative Complications. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Level of evidence.
576 Vierhout ME. Ultrasound in the diagnosis and management of stress urinary incontinence. Paper presented at: XVII FIGO World Congress of Gynecology and Obstetrics. Santiago (Chile). 2–7 Nov 2003. (World Meeting Number 000 7240). Level of evidence.
577 von Bargen A, Olianas R, Fisch M. The Transcaverneous Cuff as Last Option for Complex Urinary Incontinence. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Level of evidence.
578 Von Gontard A, Hollmann E. Comorbidity of functional urinary incontinence and encopresis: Somatic and behavioral associations. Journal of Urology. 2004;171(6 II):2644-7. Level of evidence. [pmid: 15118441].
579 Wachter J, Henning A, Ponholzer A, et al. Minimal Invasive Treatment of Female Urinary Incontinence with Adjustable Continence Therapy. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Level of evidence.
580 Wang F, Song Y, Huang H. Long-Term Outcome of the Tension-Free Vaginal Tape for Treatment of Stress Urinary Incontinence in Southeast of China: Results of Efficacy and Analysis of Failure. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep – 3 Oct 2009. Level of evidence.
581 Wang X, Hu C, Wang H, et al. A novel wireless electrical muscle simulator for female urinary incontinence. 2008. Level of evidence.
582 Watt M, Paul P, Cassisi JE. Biofeedback-assisted kegel exercises for urinary incontinence: A controlled treatment outcome study using non-invasive surface EMG. Paper presented at: 25th Annual Meeting of the Association for Applied Psychophysiology and Biofeedback: The Challenge of the Future. Atlanta, GA (USA). 3–8 Mar 1994. (World Meeting Number 941 0396). Level of evidence.
583 Whitehead WE, Norton NJ, Wald A. Introduction. Advancing the treatment of fecal and urinary incontinence through research. Gastroenterology. 2004;126(1 Suppl 1). Level of evidence.
584 Whitehead WE, Norton NJ, Wald A. Proceedings of a Consensus Conference: Advancing the treatment of Fecal and Urinary Incontinence Through Research. Trial Design, Outcome Measures, and Research Priorities - November 3 to 5, 2002, Milwaukee Wiscnsin: Introduction. Gastroenterology. 2004;126(1). Level of evidence.
585 Wieczorek P, Kryza R, Fortling B. Novel Ultrasound Techniques in the Assessment of Female Urethra Complex in the Diagnosis of Urinary Incontinence. Paper presented at: 17th European Congress of Ultrasound in Medicine and Biology (EUROSON 2005), Palexpo Congress and Exhibition Centre. Geneva (Switzerland). 25–28 Sep 2005. Level of evidence.
586 Wong KJ, Fung BKY, Fung ESM, et al. Randomized prospective study of the effectiveness of pelvic floor training using biofeedback in the treatment of genuine stress urinary incontinence in Chinese population. Paper presented at: 27th Annual Meeting of the International Continence Society. Yokohama (Japan). 23–26 Sep 1997. (World Meeting Number 973 0118). Level of evidence.
587 Wong KS, Fung BKY, Fung LCW, et al. Pelvic floor exercises in the treatment of stress urinary incontinence in Hong Kong Chinese women. Paper presented at: 27th Annual Meeting of the International Continence Society. Yokohama (Japan). 23–26 Sep 1997. (World Meeting Number 973 0118). Level of evidence.
588 Woodman J, Ramanan S, Pitkin J. Association between Urogenital Atrophy and Cystometric Diagnosis of Urinary Incontinence. Paper presented at: 8th European Congress on Menopause (EMAS 2009). ExCel Centre, London (UK). 16–20 May 2009. Level of evidence.
589 Wyman JF, Fantl JA, McClish DK, et al. Comparative efficacy of behavioral interventions in the management of female urinary incontinence. American Journal of Obstetrics and Gynecology. 1998;179(4):999-1007. Level of evidence. [pmid: 9790388].
590 Yim PS, Peterson AS. Urinary incontinence: Basic types and their management in older patients. Postgraduate Medicine. 1996;99(5):137-50. Level of evidence. [pmid: 8650081].
591 Yu LC, Hu TW, Igou J, et al. Behavioral therapy for urinary incontinence. Paper presented at: American Public Health Association 116th Annual Meeting. Boston, MA (USA). 13–17 Nov 1988. (World Meeting Number 884 0704). Level of evidence.
592 Zanetti G, Ceresoli A, Seveso M, et al. Pelvic floor exercises in the conservative treatment of female urinary incontinence. LA GINNASTICA ISOMETRICA DEL PIANO PERINEALE COME TRATTAMENTO CONSERVATIVO DELL’INCONTINENZA URINARIA FEMMINILE. 1992;6(SUPPL 4):243-4. Level of evidence.
593 Zeng X, Jack G, Zhang R, et al. Fibroblasts and Adipose Derived Stem Cells in the Treatment of Stress Urinary Incontinence: Comparison of Functional Outcomes. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Level of evidence.
594 Zhu L. A Prospective Randomised Trial Comparing Tension Free Vaginal and Transobturator Suburethral Tape for Surgical Treatment of Slight and Moderate Stress Urinary Incontinence. Paper presented at: XVIII FIGO World Congress of Gynecology and Obstetrics (FIGO 2006), Kuala Lumpur Convention Centre (KLCC). Kuala Lumpur (Malaysia). 5–10 Nov 2006. Level of evidence.
595 Zinner N, Scholfield D, Soma K, et al. A Phase 2, 8-Week, Multi-Center, Randomized Double-Blind, Placebo Controlled, Parallel Group Study Evaluating the Efficacy, Tolerability and Safety of [S,S] - Reboxetine (PNU-165442G) for Stress Urinary Incontinence in Women. Paper presented at: 2008 Annual Meeting of the American Urological Association. Orlando, Florida (USA). 17–22 May 2008. Level of evidence.
596 Zinner N, Scholfield D, Soma K, et al. Improvement in Incontinence Quality of Life (I-QOL) and Patient Global Impression of Change (PGIC) Measures in Women with Stress Urinary Incontinence (SUI) Following Treatment with [S,S] - Reboxetine (SS-RBX). Paper presented at: 2008 Annual Meeting of the American Urological Association. Orlando, Florida (USA). 17–22 May 2008. Level of evidence.
597 Ziv E, Stanton SL, Abarbanel J. The Leak Score - a novel instrument to assess subjective severity of female stress urinary incontinence and efficacy of treatment. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Level of evidence.
598 Zullo MA, Plotti F, Bellati F, et al. Transurethral polydimethylsiloxane implantation: A valid option for the treatment of stress urinary incontinence due to intrinsic sphincter deficiency without urethral hypermobility. Journal of Urology. 2005;173(3):898-902. Level of evidence. [pmid: 15711314].
599 Chan I, Brown AR, Park K, et al. Ultrasound-guided, percutaneous peripheral nerve stimulation: technical note. Neurosurgery. Sep. 2010;67(3 Suppl Operative):ons136-9. Case Report. [pmid: 20679937].
600 NIH state-of-the-science conference statement on prevention of fecal and urinary incontinence in adults. NIH Consens State Sci Statements. Dec. 12–14. 2007;24(1):1-37. Consensus conference. [pmid: 18183046].
601 Effects of terodiline on urinary incontinence among older non-institutionalized women. Terodiline in the Elderly American Multicenter Study Group. J Am Geriatr Soc. Sep. 1993;41(9):915-22. Not eligible exposure. [pmid: 8409177].
602 Incontinence Causes, management and provision of services A Working Party of the Royal College of Physicians. J R Coll Physicians Lond. Jul–Aug. 1995;29(4):272-4. Guideline. [pmid: 7473319].
603 A modest proposal: patient underwear in OR. OR Manager. Jun. 1997;13(6):23. Comment. [pmid: 10173041].
604 One nurse is sick of care homes that smell of incontinence. Nurs Times. Jul. 1–7. 1998;94(26):59. Comment. [pmid: 9739710].
605 Establishment of wound ostomy continence clinics. J Wound Ostomy Continence Nurs. Sep. 1998;25(5). 22A, 4A, 6A passim. Comment. [pmid: 9923252].
606 Dealing sensitively with incontinence. Aust Nurs J. Jun. 1999;6(11):29. Comment. [pmid: 10568413].
607 Clinical advances in incontinence management. A sampling of products now available to manage urinary incontinence. Adv Skin Wound Care. Nov–Dec. 2000;13(6):290-2. Comment. [pmid: 12669676].
608 S-oxybutynin. Drugs R D. 2002;3(2):84-5. Comment. [pmid: 12001823].
609 Developing a unique patient advocate. Ostomy Wound Manage. Dec. 2003;49(12):11-2. Comment. [pmid: 15005081].
610 Trospium chloride (Sanctura): another anticholinergic for overactive bladder. Med Lett Drugs Ther. Aug. 2. 2004;46(1188):63-4. Comment. [pmid: 15289745].
611 Solifenacin and darifenacin for overactive bladder. Obstet Gynecol. Aug. 2005;106(2):401-2. Comment. [pmid: 16055596].
612 Urinary incontinence. Know your drug options. Mayo Clin Health Lett. Nov. 2005;23(11):6. Comment. [pmid: 16419295].
613 Stem cells may cure urinary incontinence. In this experimental treatment, a patient’s own cells can stop leaks in as little as one day. Health News. Mar. 2005;11(3):4-5. News. [pmid: 15803568].
614 Duloxetine: new drug. For stress urinary incontinence: too much risk, too little benefit. Prescrire Int. Dec. 2005;14(80):218-20. Comment. [pmid: 16400743].
615 Hormone replacement therapy aggravates postmenopausal urinary incontinence. Prescrire Int. Aug. 2006;15(84):137-8. Comment. [pmid: 16989027].
616 Promoting urinary continence in older people. Nurs Older People. Apr. 2006;18(3):35-6. Comment. [pmid: 16634393].
617 Tolterodine. Nurs Times. Jun. 6–12. 2006;102(23):27. Comment. [pmid: 16784047].
618 Expression of concern--autologous myoblasts and fibroblasts versus collagen [corrected] for treatment of stress urinary incontinence in women: a [corrected] randomised controlled trial. Lancet. May. 3. 2008;371(9623):1490. Comment. [pmid: 18456089].
619 Continence assessment. Paediatric nursing. Apr. 2008;20(3):23. Comment. [pmid: 18500137].
620 Hormone therapy. An update on risks and benefits. Mayo Clin Womens Healthsource. Mar. 2009;(Suppl):1-8. Comment. [pmid: 19405167].
621 Shaw C, Williams KS, Assassa RP. Patients’ views of a new nurse-led continence service. J Clin Nurs. Jul. 2000;9(4):574-82. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11261138].
622 Aaron R, Muliyil J, Abraham S. Medico-social dimensions of menopause: a cross-sectional study from rural south India. Natl Med J India. Jan–Feb. 2002;15(1):14-7. Not eligible target population. [pmid: 11855585].
623 Abdel-Fattah M, Barrington JW, Arunkalaivanan AS. Pelvicol pubovaginal sling versus tension-free vaginal tape for treatment of urodynamic stress incontinence: a prospective randomized three-year follow-up study. Eur Urol. Nov. 2004;46(5):629-35. Not eligible exposure. [pmid: 15474274].
624 Abdel-Fattah M, Ramsay I. Transobturator tension free vaginal tapes: are they the way forward in the surgical treatment of urodynamic stress incontinence?. Int J Surg. Feb. 2007;5(1):3-10. Not eligible exposure. [pmid: 17386907].
625 Abdel-Hady el S, Constantine G. Outcome of the use of tension-free vaginal tape in women with mixed urinary incontinence, previous failed surgery, or low valsalva pressure. J Obstet Gynaecol Res. Feb. 2005;31(1):38-42. Not eligible exposure. [pmid: 15669990].
626 Abdel-Mageed AB, Bajwa A, Shenassa BB, et al. NF-kappaB-dependent gene expression of proinflammatory cytokines in T24 cells: possible role in interstitial cystitis. Urol Res. Oct. 2003;31(5):300-5. Not eligible outcomes. [pmid: 14574533].
627 Abdul MA, Yusuf MD, Liadi S, et al. Congenital vaginal fistula from a single system ectopic ureter: A case report. Niger J Med. Oct–Dec. 2006;15(4):441-3. Not eligible target population. [pmid: 17111735].
628 Abeygunasekera AM. Clean intermittent catheterisation. Ceylon Med J. Dec. 2004;49(4):107-9. no associative hypothesis tested. [pmid: 15693447].
629 Aboseif S, Tamaddon K, Chalfin S, et al. Sacral neuromodulation as an effective treatment for refractory pelvic floor dysfunction. Urology. Jul. 2002;60(1):52-6. Not eligible exposure. [pmid: 12100921].
630 Aboseif SR, Kim DH, Rieder JM, et al. Sacral neuromodulation: cost considerations and clinical benefits. Urology. Dec. 2007;70(6):1069-73. discussion 73–4. Not eligible outcomes. [pmid: 18158016].
631 Abouassaly R, Lane BR, Lakin MM, et al. Ejaculatory urine incontinence after radical prostatectomy. Urology. Dec. 2006;68(6):1248-52. Not eligible target population. [pmid: 17141827].
632 Abouassaly R, Steinberg JR, Lemieux M, et al. Complications of tension-free vaginal tape surgery: a multi-institutional review. BJU Int. Jul. 2004;94(1):110-3. Not eligible exposure. [pmid: 15217442].
633 Abrams P. Identifying and evaluating urinary incontinence in a female population. Eur Urol. 1997;32(Suppl 2):1-2. Comment. [pmid: 9248805].
634 Abrams P. Impact of Stress Urinary Incontinence on Quality of Life. Advanced Studies in Medicine. 2003;3(8 E). Review.
635 Abrams P. Urgency: the key to defining the overactive bladder. BJU Int. Sep. 2005;96(Suppl 1):1-3. Review. [pmid: 16086672].
636 Abrams P, Artibani W, Cardozo L, et al. Reviewing the ICS 2002 terminology report: the ongoing debate. Neurourol Urodyn. 2009;28(4):287. Review. [pmid: 19350662].
637 Abrams P, Cardozo L, Fall M, et al. The standardisation of terminology of lower urinary tract function: report from the Standardisation Sub-committee of the International Continence Society. Neurourol Urodyn. 2002;21(2):167-78. Review. [pmid: 11857671].
638 Abrams P, Donovan JL, de la Rosette JJ, et al. International Continence Society “Benign Prostatic Hyperplasia” Study: background, aims, and methodology. Neurourol Urodyn. 1997;16(2):79-91. Not eligible target population. [pmid: 9042670].
639 Abrams P, Kaplan S, De Koning Gans HJ, et al. Safety and tolerability of tolterodine for the treatment of overactive bladder in men with bladder outlet obstruction. J Urol. Mar. 2006;175(3 Pt 1):999-1004. discussion. Not eligible target population. [pmid: 16469601].
640 Abrams P, Klevmark B. Frequency volume charts: an indispensable part of lower urinary tract assessment. Scand J Urol Nephrol Suppl. 1996;179:47-53. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8908664].
641 Abrams P, Swift S. Solifenacin is effective for the treatment of OAB dry patients: a pooled analysis. Eur Urol. Sep. 2005;48(3):483-7. Not eligible target population. [pmid: 16005564].
642 Adamiak A, Milart P, Skorupski P, et al. The efficacy and safety of the tension-free vaginal tape procedure do not depend on the method of analgesia. Eur Urol. Jul. 2002;42(1):29-33. Not eligible exposure. [pmid: 12121726].
643 Adamyan L, Kozachenko I, Sashin B. Treatment of Mixed Urinary Incontinence with Intra-Detrusor Injection of Botulinuma Toxin. Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Not eligible case reports.
644 Addington-Hall J, Lay M, Altmann D, et al. Symptom control, communication with health professionals, and hospital care of stroke patients in the last year of life as reported by surviving family, friends, and officials. Stroke. Dec. 1995;26(12):2242-8. Not eligible target population. [pmid: 7491644].
645 Addison R. Intermittent self-catheterisation. Nurs Times. May. 17–23. 2001;97(20):67-9. Not eligible exposure. [pmid: 11962054].
646 Adekanmi OA, Freeman RM, Bombieri L. How colposuspensions are performed in the UK: a survey of gynecologists’ practice. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2003;14(3):151-9. discussion 9. Not eligible exposure. [pmid: 12955335].
647 Adkins VK, Mathews RM. Prompted voiding to reduce incontinence in community-dwelling older adults. J Appl Behav Anal. Spring. 1997;30(1):153-6. Comment. [pmid: 9103990].
648 Adler US, Kirshblum SC. A new assistive device for intermittent self-catheterization in men with tetraplegia. J Spinal Cord Med. Summer. 2003;26(2):155-8. Not eligible target population. [pmid: 12828294].
649 Agarwal A, Dhiraaj S, Singhal V, et al. Comparison of efficacy of oxybutynin and tolterodine for prevention of catheter related bladder discomfort: a prospective, randomized, placebo-controlled, double-blind study. Br J Anaesth. Mar. 2006;96(3):377-80. Not eligible target population. [pmid: 16415311].
650 Agnew G, Byrne P. The evaluation and treatment of female urinary incontinence--a comparison of clinical practice in the Republic of Ireland with the recommendations of the International Continence Society. Ir Med J. Sep. 2004;97(8):238-40. Not eligible target population. [pmid: 15532970].
651 Agur WI, Steggles P, Waterfield M, et al. The long-term effectiveness of antenatal pelvic floor muscle training: eight-year follow up of a randomised controlled trial. BJOG. Jul. 2008;115(8):985-90. Not eligible target population. [pmid: 18651881].
652 AHCPR Urinary Incontinence in Adults Guideline Update Panel. Managing acute and chronic urinary incontinence. Am Fam Physician. 1996;54:1661-72. Not eligible Review. [pmid: 8857788].
653 Ahmed S, Davies J. Managing the complications of prostate cryosurgery. BJU Int. Mar. 2005;95(4):480-1. Not eligible target population. [pmid: 15705063].
654 Akakura K, Isaka S, Akimoto S, et al. Long-term results of a randomized trial for the treatment of Stages B2 and C prostate cancer: radical prostatectomy versus external beam radiation therapy with a common endocrine therapy in both modalities. Urology. Aug. 1999;54(2):313-8. Not eligible target population. [pmid: 10443731].
655 Akbal C, Genc Y, Burgu B, et al. Dysfunctional voiding and incontinence scoring system: quantitative evaluation of incontinence symptoms in pediatric population. J Urol. Mar. 2005;173(3):969-73. Not eligible target population. [pmid: 15711352].
656 Al-Abany M, Helgason AR, Adolfsson J, et al. Reliability of assessment of urgency and other symptoms indicating anal sphincter, large bowel or urinary dysfunction. Scand J Urol Nephrol. 2006;40(5):397-408. Not eligible target population. [pmid: 17060087].
657 Alam SM, Hoq MM, Hoque M, et al. Initial experience with 10 cases of Indiana pouch continent urinary diversion. Bangladesh Med Res Counc Bull. Apr. 2008;34(1):21-5. Not eligible exposure. [pmid: 18783073].
658 Albani JM, Zippe CD. Urethral catheter removal 3 days after radical retropubic prostatectomy is feasible and desirable. Prostate Cancer Prostatic Dis. 2002;5(4):291-5. Not eligible target population. [pmid: 12627214].
659 Albers-Heitner P, Berghmans B, Joore M, et al. The effects of involving a nurse practitioner in primary care for adult patients with urinary incontinence: the PromoCon study (Promoting Continence). BMC Health Serv Res. 2008;8:84. Not associative hypothesis tested. [pmid: 18412964].
660 Albers-Heitner P, Berghmans B, Nieman F, et al. How do patients with urinary incontinence perceive care given by their general practitioner? A cross-sectional study. International journal of clinical practice. Mar. 2008;62(3):508-15. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18261081].
661 Albertsen PC. Clinical and physical determinants for toxicity of 125-I seed prostate brachytherapy. J Urol. Nov. 2005;174(5):1969-70. Not eligible target population. [pmid: 16217368].
662 Albo M, Wruck L, Baker J, et al. The relationships among measures of incontinence severity in women undergoing surgery for stress urinary incontinence. J Urol. May. 2007;177(5):1810-4. Not eligible exposure. [pmid: 17437826].
663 Albo ME, Richter HE, Brubaker L, et al. Burch colposuspension versus fascial sling to reduce urinary stress incontinence. N Engl J Med. May. 24. 2007;356(21):2143-55. Not eligible exposure. [pmid: 17517855].
664 Alcalay M, Thompson PK, Boone TB. Ball urethroplasty combined with Marshall-Marchetti-Krantz urethropexy versus suburethral sling in patients with intrinsic sphincter deficiency and urethral hypermobility. Am J Obstet Gynecol. Dec. 2000;183(6):1348-53. discussion 53–4. Not eligible exposure. [pmid: 11120495].
665 Alessi CA, Josephson KR, Harker JO, et al. The yield, reliability, and validity of a postal survey for screening community-dwelling older people. J Am Geriatr Soc. Feb. 2003;51(2):194-202. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12558716].
666 Alessi CA, Ouslander JG, Maldague S, et al. Incidence and costs of acute medical conditions in long-stay incontinent nursing home residents. J Am Med Dir Assoc. Mar–Apr. 2003;4(2 Suppl):S4-18. Not eligible target population. [pmid: 12807565].
667 Alessi CA, Schnelle JF, MacRae PG, et al. Does physical activity improve sleep in impaired nursing home residents?. J Am Geriatr Soc. Oct. 1995;43(10):1098-102. Not eligible target population. [pmid: 7560698].
668 Alessi CA, Yoon EJ, Schnelle JF, et al. A randomized trial of a combined physical activity and environmental intervention in nursing home residents: do sleep and agitation improve?. J Am Geriatr Soc. Jul. 1999;47(7):784-91. Not eligible population. [pmid: 10404920].
669 Alewijnse D, Mesters I, Metsemakers J, et al. Predictors of intention to adhere to physiotherapy among women with urinary incontinence. Health Educ Res. Apr. 2001;16(2):173-86. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11345660].
670 Alewijnse D, Mesters I, Metsemakers J, et al. Predictors of long-term adherence to pelvic floor muscle exercise therapy among women with urinary incontinence. Health Educ Res. Oct. 2003;18(5):511-24. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14572013].
671 Alewijnse D, Mesters IE, Metsemakers JF, et al. Program development for promoting adherence during and after exercise therapy for urinary incontinence. Patient Educ Couns. Oct–Nov. 2002;48(2):147-60. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12401418].
672 Alfano CM, McGregor BA, Kuniyuki A, et al. Psychometric properties of a tool for measuring hormone-related symptoms in breast cancer survivors. Psychooncology. Nov. 2006;15(11):985-1000. Not eligible target population. [pmid: 16470891].
673 Al-Jadid MS, Al-Asmari AK, Al-Moutaery KR. Quality of life in males with spinal cord injury in Saudi Arabia. Saudi Med J. Dec. 2004;25(12):1979-85. Not eligible target population. [pmid: 15711680].
674 Allahdin S, McKinley C, Mahmood TA, et al. Tension-free vaginal tape: 162 cases in a district general hospital. J Obstet Gynaecol. Aug. 2004;24(5):539-41. Not eligible exposure. [pmid: 15369936].
675 Allahdin S, McKinley CA, Mahmood TA. Tension free vaginal tape: a procedure for all ages. Acta Obstet Gynecol Scand. Oct. 2004;83(10):937-40. Not eligible exposure. [pmid: 15453889].
676 Allahdin S, Oo N, Jones C. Intractable flatus incontinence treated by percutaneous tibial nerve stimulation. Int J Colorectal Dis. 2011. Jan. 6. Not eligible target population. [pmid: 21210132].
677 Allareddy V, Kennedy J, West MM, et al. Quality of life in long-term survivors of bladder cancer. Cancer. Jun. 1. 2006;106(11):2355-62. Not eligible target population. [pmid: 16649218].
678 Alloussi S, Alloussi SH, Eichel R, et al. Post-Prostatectomy Stress Urinary Incontinence: Long Term Follow Up after Injection Treatment with Non-Animal Stabilized Dextranomer/Hyaluronic Acid (NASHA/DX). Paper presented at: 2008 Annual Meeting of the American Urological Association. Orlando, Florida (USA). 17–22 May 2008. Not eligible target population.
679 Allsworth JE, Omicioli VA, Cunkelman JA, et al. Discussion: ‘Reproductive factors associated with nocturia and urgency’ by Tikkinen et al. Am J Obstet Gynecol. Aug. 2008;199(2):e1-3. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18674651].
680 Allsworth JE, Omicioli VA, Cunkelman JA, et al. Reproductive factors associated with nocturia and urgency: Tikkinen et al. Am J Obstet Gynecol. Aug. 2008;199(2):205-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18674664].
681 Almeida FG, Bruschini H, Srougi M. Urodynamic and clinical evaluation of 91 female patients with urinary incontinence treated with perineal magnetic stimulation: 1-year followup. J Urol. Apr. 2004;171(4):1571-4. discussion 4–5. Level of evidence. [pmid: 15017223].
682 Almodhen F, Capolicchio JP, Jednak R, et al. Postpubertal urodynamic and upper urinary tract changes in children with conservatively treated myelomeningocele. J Urol. Oct. 2007;178(4 Pt 1):1479-82. Not eligible target population. [pmid: 17706702].
683 Al-Samarrai NR, Uman GC, Al-Samarrai T, et al. Introducing a new incontinence management system for nursing home residents. J Am Med Dir Assoc. May. 2007;8(4):253-61. Not eligible target population. [pmid: 17498610].
684 Al-Singary W, Shergill IS, Allen SE, et al. Trans-obturator tape for incontinence: a 3-year follow-up. Urol Int. 2007;78(3):198-201. Not eligible exposure. [pmid: 17406126].
685 Altinova S, Demirci DA, Ozdemir AT, et al. Incorporation of anterior rectus fascial sling into radical retropubic prostatectomy improves postoperative continence. Urol Int. 2009;83(1):19-21. Not eligible target population. [pmid: 19641353].
686 Altman D, Vayrynen T, Engh ME, et al. Short-term outcome after transvaginal mesh repair of pelvic organ prolapse. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2008;19(6):787-93. Not eligible exposure. [pmid: 18074068].
687 Altomare DF, Rinaldi M, Petrolino M, et al. Permanent sacral nerve modulation for fecal incontinence and associated urinary disturbances. Int J Colorectal Dis. May. 2004;19(3):203-9. Not eligible target population. [pmid: 13680281].
688 Altwein J, Ekman P, Barry M, et al. How is quality of life in prostate cancer patients influenced by modern treatment? The Wallenberg Symposium. Urology. Apr. 1997;49(4A Suppl):66-76. Not eligible target population. [pmid: 9111616].
689 Al-Waili NS. Carbamazepine to treat primary nocturnal enuresis: double-blind study. Eur J Med Res. Jan. 26. 2000;5(1):40-4. Not eligible target population. [pmid: 10657288].
690 Amark P, Beck O. Effect of phenylpropanolamine on incontinence in children with neurogenic bladders. A double-blind crossover study. Acta Paediatr. Apr. 1992;81(4):345-50. Not eligible target population. [pmid: 1606397].
691 Amark P, Bussman G, Eksborg S. Follow-up of long-time treatment with intravesical oxybutynin for neurogenic bladder in children. Eur Urol. Aug. 1998;34(2):148-53. Not eligible target population. [pmid: 9693251].
692 Amark P, Eksborg S, Juneskans O, et al. Pharmacokinetics and effects of intravesical oxybutynin on the paediatric neurogenic bladder. Br J Urol. Dec. 1998;82(6):859-64. Not eligible target population. [pmid: 9883225].
693 Ames D, Hastie IR. Urinary incontinence. Postgrad Med J. Apr. 1995;71(834):195-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7784273].
694 Amrute KV, Eisenberg ER, Rastinehad AR, et al. Analysis of outcomes of single polypropylene mesh in total pelvic floor reconstruction. Neurourol Urodyn. 2007;26(1):53-8. Not eligible exposure. [pmid: 17080416].
695 Amundsen CL, Guralnick ML, Webster GD. Variations in strategy for the treatment of urethral obstruction after a pubovaginal sling procedure. J Urol. Aug. 2000;164(2):434-7. Not eligible exposure. [pmid: 10893603].
696 Amundsen CL, Parsons M, Tissot B, et al. Bladder diary measurements in asymptomatic females: functional bladder capacity, frequency, and 24-hr volume. Neurourol Urodyn. 2007;26(3):341-9. no associated hypothesis tested. [pmid: 17315222].
697 Amundsen CL, Visco AG, Ruiz H, et al. Outcome in 104 pubovaginal slings using freeze-dried allograft fascia lata from a single tissue bank. Urology. Dec. 4. 2000;56(6 Suppl 1):2-8. Not eligible exposure. [pmid: 11114556].
698 Amundsen CL, Webster GD. Sacral neuromodulation in an older, urge-incontinent population. Am J Obstet Gynecol. Dec. 2002;187(6):1462-5. discussion 5. Case-series. [pmid: 12501047].
699 Anand KB, Wolf-Klein GP, Silverstone FA, et al. Demographic changes and their financial implications. Clin Geriatr Med. Feb. 1990;6(1):1-12. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 2302647].
700 Anders K. Treatments for stress urinary incontinence. Nurs Times. Jan. 10–16. 2006;102(2):55-7. Comment. [pmid: 16429695].
701 Anderson CL. The use of Ditropan in the elderly: nursing responsibilities. Perspectives. Fall. 1993;17(3):11. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8116314].
702 Anderson CS, Jamrozik KD, Broadhurst RJ, et al. Predicting survival for 1 year among different subtypes of stroke. Results from the Perth Community Stroke Study. Stroke. Oct. 1994;25(10):1935-44. Not eligible target population. [pmid: 8091436].
703 Anderson KD, Borisoff JF, Johnson RD, et al. The impact of spinal cord injury on sexual function: concerns of the general population. Spinal Cord. May. 2007;45(5):328-37. Not eligible target population. [pmid: 17033620].
704 Anderson P. Promoting continence care and creating awareness. Community Nurse. May. 1999;5(4):31-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10513536].
705 Andersson G, Johansson JE, Nilsson K, et al. Accepting and adjusting: older women’s experiences of living with urinary incontinence. Urol Nurs. Apr. 2008;28(2):115-21. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18488587].
706 Andersson G, Johansson JE, Sahlberg-Blom E, et al. Urinary incontinence--why refraining from treatment? A population based study. Scand J Urol Nephrol. 2005;39(4):301-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16118105].
707 Andonian S, Chen T, St-Denis B, et al. Randomized clinical trial comparing suprapubic arch sling (SPARC) and tension-free vaginal tape (TVT): one-year results. Eur Urol. Apr. 2005;47(4):537-41. Not eligible exposure. [pmid: 15774255].
708 Andonian S, St-Denis B, Lemieux MC, et al. Prospective clinical trial comparing Obtape and DUPS to TVT: one-year safety and efficacy results. Eur Urol. Jul. 2007;52(1):245-51. Not eligible exposure. [pmid: 17234331].
709 Anger JT, Saigal CS, Madison R, et al. Increasing costs of urinary incontinence among female Medicare beneficiaries. J Urol. Jul. 2006;176(1):247-51. discussion 51. Not eligible outcomes. [pmid: 16753411].
710 Angioli R, Zullo MA, Plotti F, et al. Urologic function and urodynamic evaluation of urinary diversion (Rome pouch) over time in gynecologic cancers patients. Gynecol Oncol. Nov. 2007;107(2):200-4. Not eligible target population. [pmid: 17692906].
711 Ankardal M, Ekerydh A, Crafoord K, et al. A randomised trial comparing open Burch colposuspension using sutures with laparoscopic colposuspension using mesh and staples in women with stress urinary incontinence. BJOG. Sep. 2004;111(9):974-81. Not eligible exposure. [pmid: 15327613].
712 Ankardal M, Heiwall B, Lausten-Thomsen N, et al. Short- and long-term results of the tension-free vaginal tape procedure in the treatment of female urinary incontinence. Acta Obstetricia et Gynecologica Scandinavica. 2006;85(8):986-92. Not eligible exposure. [pmid: 16862480].
713 Ankardal M, Milsom I, Stjerndahl JH, et al. A three-armed randomized trial comparing open Burch colposuspension using sutures with laparoscopic colposuspension using sutures and laparoscopic colposuspension using mesh and staples in women with stress urinary incontinence. Acta Obstetricia et Gynecologica Scandinavica. Aug. 2005;84(8):773-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16026404].
714 Anthony B. The provision of continence supplies by NHS trusts. Elder Care. 1997 Dec–1998 Jan. 9(6 Suppl):4-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9511660].
715 Antonakos CL, Miller JM, Sampselle CM. Indices for studying urinary incontinence and levator ani function in primiparous women. J Clin Nurs. Jul. 2003;12(4):554-61. Not eligible outcomes. [pmid: 12790869].
716 Antovska SV, Dimitrov DG. Vaginosacral colpopexy (VSC)--a new modification of the Mc Call operation using vaginosacral ligaments as autologous sliding grafts in posthysterectomy vault prolapse. Bratisl Lek Listy. 2006;107(3):62-72. Not eligible exposure. [pmid: 16796126].
717 Appell RA. Electrical stimulation for the treatment of urinary incontinence. Urology. 1998;51(2 SUPPL A):24-6. Not eligible review. [pmid: 9495731].
718 Appell RA. Surgery or collagen for the treatment of female stress urinary incontinence: results of a multicenter, randomized trial supports either as first line of treatment. Curr Urol Rep. Oct. 2001;2(5):343. Not eligible exposure. [pmid: 12084239].
719 Appell RA. Transurethral collagen denaturation for women with stress urinary incontinence. Curr Urol Rep. Sep. 2008;9(5):373-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18702921].
720 Araco F, Gravante G, Sorge R, et al. TVT-O vs TVT: a randomized trial in patients with different degrees of urinary stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Jul. 2008;19(7):917-26. Not eligible exposure. [pmid: 18217177].
721 Arai Y, Okubo K, Aoki Y, et al. Patient-reported quality of life after radical prostatectomy for prostate cancer. Int J Urol. Feb. 1999;6(2):78-86. Not eligible target population. [pmid: 10226812].
722 Araki I, Beppu M, Kajiwara M, et al. Prevalence and impact on generic quality of life of urinary incontinence in Japanese working women: assessment by ICI questionnaire and SF-36 Health Survey. Urology. Jul. 2005;66(1):88-93. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15992871].
723 Araki I, Kuno S. Assessment of voiding dysfunction in Parkinson’s disease by the international prostate symptom score. J Neurol Neurosurg Psychiatry. Apr. 2000;68(4):429-33. Not eligible target population. [pmid: 10727477].
724 Araki I, Zakoji H, Komuro M, et al. Lower urinary tract symptoms in men and women without underlying disease causing micturition disorder: a cross-sectional study assessing the natural history of bladder function. J Urol. Nov. 2003;170(5):1901-4. Not eligible outcomes. [pmid: 14532803].
725 Armstrong SM, Miller JM, Benson K, et al. Revisiting reliability of quantified perineal ultrasound: Bland and Altman analysis of a new protocol for the rectangular coordinate method. Neurourol Urodyn. 2006;25(7):731-8. Not eligible outcomes. [pmid: 16897749].
726 Artibani W, Pesce F, Prezioso D, et al. Italian validation of the urogenital distress inventory and its application in LUTS patients. Eur Urol. Dec. 2006;50(6):1323-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16713067].
727 Arunkalaivanan AS, Barrington JW. Randomized trial of porcine dermal sling (Pelvicol implant) vs. tension-free vaginal tape (TVT) in the surgical treatment of stress incontinence: a questionnaire-based study. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2003;14(1):17-23. discussion 1–2. Not eligible exposure. [pmid: 12601511].
728 Arunkalaivanan AS, Barrington JW. Questionnaire-based survey on obstetricians and gynaecologists’ attitudes towards the surgical management of urinary incontinence in women during their childbearing years. Eur J Obstet Gynecol Reprod Biol. May. 1. 2003;108(1):85-93. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12694977].
729 Asbury N. Mines of information. Nurs Times. May. 5–11. 1999;95(18):85-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10373922].
730 Ashworth PD, Hagan MT. The meaning of incontinence: a qualitative study of non-geriatric urinary incontinence sufferers. J Adv Nurs. Sep. 1993;18(9):1415-23. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8258600].
731 Aslan E, Beji NK, Coskun A, et al. An assessment of the importance of pad testing in stress urinary incontinence and the effects of incontinence on the life quality of women. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2003;14(5):316-9. discussion 20. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14618307].
732 Aslan E, Komurcu N, Beji NK, et al. Bladder training and Kegel exercises for women with urinary complaints living in a rest home. Gerontology. 2008;54(4):224-31. Not eligible target population. [pmid: 18483451].
733 Assassa RP, Kang J, Dean N. Escalating the Dose of Duloxetine. An Audit of Tolerability and Efficacy in Clinical Practice. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Not eligible case studies.
734 Aswathaman K, Devasia A. Thimble bladder. ANZ Journal of Surgery. Nov. 2008;78(11):1049. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18959724].
735 Atan A, Konety BR, Erickson JR, et al. Tolterodine for overactive bladder: time to onset of action, preferred dosage, and 9-month follow-up. Tech Urol. Jun. 1999;5(2):67-70. Level of evidence. [pmid: 10458657].
736 Athanasiou S, Chaliha C, Digesu GA, et al. The effects of duloxetine on urethral function and sphincter morphology. Int Urogynecol J Pelvic Floor Dysfunct. Jul. 2007;18(7):763-7. Case-series. [pmid: 17061027].
737 Athanasopoulos A, Gyftopoulos K, Giannitsas K, et al. Combination treatment with an alpha-blocker plus an anticholinergic for bladder outlet obstruction: a prospective, randomized, controlled study. J Urol. Jun. 2003;169(6):2253-6. Not eligible target population. [pmid: 12771763].
738 Athanassopoulos A, Barbalias G. Burch colposuspension versus stamey endoscopic bladder neck suspension: a urodynamic appraisal. Urol Int. 1996;56(1):23-7. Not eligible exposure. [pmid: 8903550].
739 Augustin H, Pummer K, Daghofer F, et al. Patient self-reporting questionnaire on urological morbidity and bother after radical retropubic prostatectomy. Eur Urol. Aug. 2002;42(2):112-17. Not eligible target population. [pmid: 12160580].
740 Austin L, Luker K, Roland M. Clinical nurse specialists as entrepreneurs: constrained or liberated. J Clin Nurs. Dec. 2006;15(12):1540-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17118076].
741 Autret E, Jonville AP, Dutertre JP, et al. Plasma levels of oxybutynine chloride in children. Eur J Clin Pharmacol. 1994;46(1):83-5. Not eligible target population. [pmid: 8005192].
742 Avedisian L, Kowalsky DS, Albro RC, et al. Abdominal strengthening using the AbVice machine as measured by surface electromyographic activation levels. J Strength Cond Res. Aug. 2005;19(3):709-12. Not eligible outcomes. [pmid: 16095429].
743 Avery JC, Gill TK, MacLennan AH, et al. The impact of incontinence on health-related quality of life in a South Australian population sample. Aust N Z J Public Health. Apr. 2004;28(2):173-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15233358].
744 Awad SA, Al-Zahrani HM, Gajewski JB, et al. Long-term results and complications of augmentation ileocystoplasty for idiopathic urge incontinence in women. Br J Urol. Apr. 1998;81(4):569-73. Not eligible exposure. [pmid: 9598629].
745 Ayhan A, Esin S, Guven S, et al. The Manchester operation for uterine prolapse. Int J Gynaecol Obstet. Mar. 2006;92(3):228-33. Not eligible exposure. [pmid: 16427641].
746 aYokoyama O, Yusup A, Oyama N, et al. Improvement of bladder storage function by alpha1-blocker depends on the suppression of C-fiber afferent activity in rats. Neurourol Urodyn. 2006;25(5):461-7. Not eligible target population. [pmid: 16673377].
747 Azuma R, Murakami K, Iwamoto M, et al. Prevalence and risk factors of urinary incontinence and its influence on the quality of life of Japanese women. Nurs Health Sci. Jun. 2008;10(2):151-8. Not eligible target population. [pmid: 18466389].
748 Baatenburg de Jong H, Admiraal H. Comparing cost per use of 3M Cavilon No Sting Barrier Film with zinc oxide oil in incontinent patients. J Wound Care. Oct. 2004;13(9):398-400. Not eligible exposure. [pmid: 15517755].
749 Babu R. Effectiveness of tolterodine in nonneurogenic voiding dysfunction. Indian Pediatr. Nov. 2006;43(11):980-3. Not eligible target population. [pmid: 17151401].
750 Bachmann CJ, Heilenkotter K, Janhsen E, et al. Long-term effects of a urotherapy training program in children with functional urinary incontinence: a 2-year follow-up. Scandinavian Journal of Urology & Nephrology. 2008;42(4):337-43. Not eligible target population. [pmid: 19230166].
751 Bachmann G. Urogenital ageing: an old problem newly recognized. Maturitas. Dec. 1995;22(Suppl):S1-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8775770].
752 Bael A, Lax H, de Jong TP, et al. The relevance of urodynamic studies for Urge syndrome and dysfunctional voiding: a multicenter controlled trial in children. J Urol. Oct. 2008;180(4):1486-93. discussion 94–5. Not eligible target population. [pmid: 18710726].
753 Bael A, Winkler P, Lax H, et al. Behavior profiles in children with functional urinary incontinence before and after incontinence treatment. Pediatrics. May. 2008;121(5):e1196-200. Not eligible target population. [pmid: 18450862].
754 Baessler K, O’Neill SM, Maher CF, et al. An interviewer-administered validated female pelvic floor questionnaire for community-based research. Menopause. Sep–Oct. 2008;15(5):973-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18458646].
755 Baessler K, Stanton SL. Does Burch colposuspension cure coital incontinence?. Am J Obstet Gynecol. Apr. 2004;190(4):1030-3. Not eligible exposure. [pmid: 15118636].
756 Bafghi A, Valerio L, Benizri EI, et al. Comparison between monofilament and multifilament polypropylene tapes in urinary incontinence. Eur J Obstet Gynecol Reprod Biol. Oct. 1. 2005;122(2):232-6. Not eligible exposure. [pmid: 16219524].
757 Bagi P, Biering-Sorensen F. Botulinum toxin A for treatment of neurogenic detrusor overactivity and incontinence in patients with spinal cord lesions. Scand J Urol Nephrol. 2004;38(6):495-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15841785].
758 Bai SW, Jung BH, Chung BC, et al. Relationship between urinary profile of the endogenous steroids and postmenopausal women with stress urinary incontinence. Neurourol Urodyn. 2003;22(3):198-205. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12707870].
759 Bai SW, Jung YW, Kwon HS, et al. The role of estrogen receptor, progesterone receptor and p53 in development of stress urinary incontinence. Yonsei Med J. Oct. 31. 2004;45(5):885-90. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15515200].
760 Bai SW, Roh JL, Kim JY, et al. Outcomes and surgical therapeutic index of Burch colposuspension in stress urinary incontinence. J Reprod Med. Feb. 2003;48(2):102-6. Not eligible exposure. [pmid: 12621793].
761 Bai SW, Sohn WH, Chung DJ, et al. Comparison of the efficacy of Burch colposuspension, pubovaginal sling, and tension-free vaginal tape for stress urinary incontinence. Int J Gynaecol Obstet. Dec. 2005;91(3):246-51. Not eligible exposure. [pmid: 16242695].
762 Baig LA, Karim SA. Age at menopause, and knowledge of and attitudes to menopause, of women in Karachi, Pakistan. J Br Menopause Soc. Jun. 2006;12(2):71-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16776858].
763 Baigis-Smith J, Smith DA, Rose M, et al. Managing urinary incontinence in community-residing elderly persons. Gerontologist. Apr. 1989;29(2):229-33. Not eligible level of evidence. [pmid: 2753383].
764 Bakas P, Liapis A, Giner M, et al. Quality of life in relation to TVT procedure for the treatment of stress urinary incontinence. Acta Obstet Gynecol Scand. 2006;85(6):748-52. Not eligible exposure. [pmid: 16752270].
765 Balakrishnan S, Lim YN, Barry C, et al. Sling distress: a subanalysis of the IVS tapes from the SUSPEND trial. Aust N Z J Obstet Gynaecol. Dec. 2007;47(6):496-8. Not eligible exposure. [pmid: 17991116].
766 Bales GT, Gerber GS, Minor TX, et al. Effect of preoperative biofeedback/pelvic floor training on continence in men undergoing radical prostatectomy. Urology. Oct. 1. 2000;56(4):627-30. Not eligible target population. [pmid: 11018619].
767 Ball JM, Bavendam TG. Quality of life assessment of women with urinary incontinence undergoing non-surgical intervention. Journal of Investigative Medicine. 1999;47(2). Not eligible case series.
768 Balmforth JR, Mantle J, Bidmead J, et al. A prospective observational trial of pelvic floor muscle training for female stress urinary incontinence. BJU Int. Oct. 2006;98(4):811-7. Level of evidence. [pmid: 16978276].
769 Bang LM, Easthope SE, Perry CM. Transdermal oxybutynin: for overactive bladder. Drugs Aging. 2003;20(11):857-64. Review. [pmid: 12964892].
770 Barbalias G, Liatsikos E, Barbalias D. Use of slings made of indigenous and allogenic material (Goretex) in type III urinary incontinence and comparison between them. Eur Urol. 1997;31(4):394-400. Not eligible exposure. [pmid: 9187896].
771 Barber MD, Kleeman S, Karram MM, et al. Risk factors associated with failure 1 year after retropubic or transobturator midurethral slings. American Journal of Obstetrics & Gynecology. Dec. 2008;199(6):666.e1-e7. Not eligible exposure. [pmid: 19084098].
772 Barber MD, Kleeman S, Karram MM, et al. Transobturator tape compared with tension-free vaginal tape for the treatment of stress urinary incontinence: a randomized controlled trial. Obstet Gynecol. Mar. 2008;111(3):611-21. Not eligible exposure. [pmid: 18310363].
773 Barber MD, Kuchibhatla MN, Pieper CF, et al. Psychometric evaluation of 2 comprehensive condition-specific quality of life instruments for women with pelvic floor disorders. Am J Obstet Gynecol. Dec. 2001;185(6):1388-95. Not eligible outcomes. [pmid: 11744914].
774 Barber MD, Visco AG, Wyman JF, et al. Sexual function in women with urinary incontinence and pelvic organ prolapse. Obstet Gynecol. Feb. 2002;99(2):281-9. Not eligible exposure. [pmid: 11814510].
775 Barber MD, Walters MD, Bump RC. Short forms of two condition-specific quality-of-life questionnaires for women with pelvic floor disorders (PFDI-20 and PFIQ-7). Am J Obstet Gynecol. Jul. 2005;193(1):103-13. Not eligible outcomes. [pmid: 16021067].
776 Barker J Jr, Wallner K, Merrick G. Gross hematuria after prostate brachytherapy. Urology. Feb. 2003;61(2):408-11. Not eligible target population. [pmid: 12597957].
777 Barreto F, Dall’Oglio M, Srougi M. Recurrent vesicourethal stenosis after radical prostatectomy: how to treat it?. Int Braz J Urol. Nov–Dec. 2005;31(6):552-4. Not eligible target population. [pmid: 16386124].
778 Barrington JW, Dyer R, Bano F. Bladder augmentation using Pelvicol implant for intractable overactive bladder syndrome. Int Urogynecol J Pelvic Floor Dysfunct. Jan. 2006;17(1):50-3. Not eligible exposure. [pmid: 16001132].
779 Barroso U Jr, Nova T, Dultra A, et al. Comparative analysis of the symptomatology of children with lower urinary tract dysfunction in relation to objective data. Int Braz J Urol. Jan–Feb. 2006;32(1):70-6. Not eligible target population. [pmid: 16519833].
780 Barry C, Lim YN, Muller R, et al. A multi-centre, randomised clinical control trial comparing the retropubic (RP) approach versus the transobturator approach (TO) for tension-free, suburethral sling treatment of urodynamic stress incontinence: the TORP study. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2008;19(2):171-8. Not eligible exposure. [pmid: 17634853].
781 Bartholomew J. District nursing. What they really, really want. Nurs Times. Mar. 24–30. 1999;95(12):30-1. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10232238].
782 Basok EK, Yildirim A, Atsu N, et al. Cadaveric fascia lata versus intravaginal slingplasty for the pubovaginal sling: surgical outcome, overall success and patient satisfaction rates. Urol Int. 2008;80(1):46-51. Not eligible exposure. [pmid: 18204233].
783 Basra RK, Wagg A, Chapple C, et al. A review of adherence to drug therapy in patients with overactive bladder. BJU Int. Sep. 2008;102(7):774-9. Review. [pmid: 18616691].
784 Bassili A, Zaki A, Zaher SR, et al. Quality of care of children with chronic diseases in Alexandria, Egypt: the models of asthma, type I diabetes, epilepsy, and rheumatic heart disease. Egyptian-Italian Collaborative Group on Pediatric Chronic Diseases. Pediatrics. Jul. 2000;106(1):E12. Not eligible target population. [pmid: 10878181].
785 Bastian PJ, Albers P, Haferkamp A, et al. Modified ureterosigmoidostomy (Mainz Pouch II) in different age groups and with different techniques of ureteric implantation. BJU Int. Aug. 2004;94(3):345-9. Not eligible target population. [pmid: 15291865].
786 Basu M, Duckett J. A randomised trial of a retropubic tension-free vaginal tape versus a mini-sling for stress incontinence. BJOG. May. 2010;117(6):730-5. Not eligible exposure. [pmid: 20175874].
787 Basu M, Duckett JR. Barriers to seeking treatment for women with persistent or recurrent symptoms in urogynaecology. BJOG. Apr. 2009;116(5):726-30. Not eligible outcomes. [pmid: 19220235].
788 Bates PM. Sharing the secret: talking about urinary incontinence. Nurs Manage. Oct. 2000;31(Suppl):8-10. 2. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15127459].
789 Bates TS, Wright MP, Gillatt DA. Prevalence and impact of incontinence and impotence following total prostatectomy assessed anonymously by the ICS-male questionnaire. Eur Urol. 1998;33(2):165-9. Not eligible target population. [pmid: 9519358].
790 Bates-Jensen BM, Alessi CA, Al-Samarrai NR, et al. The effects of an exercise and incontinence intervention on skin health outcomes in nursing home residents. J Am Geriatr Soc. Mar. 2003;51(3):348-55. Not eligible target population. [pmid: 12588578].
791 Batista JE, Bauer SB, Shefner JM, et al. Urodynamic findings in children with spinal cord ischemia. J Urol. Sep. 1995;154(3):1183-7. Not eligible target population. [pmid: 7637085].
792 Bau MO, Younes S, Aupy A, et al. The Malone antegrade colonic enema isolated or associated with urological incontinence procedures: evaluation from patient point of view. J Urol. Jun. 2001;165(6 Pt 2):2399-403. Not eligible target population. [pmid: 11371986].
793 Bayliss V, Cherry M, Locke R, et al. Pathways for continence care: background and audit. Br J Nurs. May. 11–24. 2000;9(9):590-2. 4. 6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11904894].
794 Bayliss V, Cherry M, Locke R, et al. Pathways for continence care: the validation process. Br J Nurs. Jan 25-Feb 7. 2001;10(2):87-90. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12170505].
795 Bayliss V, Salter L. Pathways for evidence-based continence care. Nurs Stand. Nov. 10–16. 2004;19(9):45-51. quiz 2. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15574054].
796 Becmeur F, Demarche M, Lacreuse I, et al. Cecostomy button for antegrade enemas: survey of 29 patients. J Pediatr Surg. Oct. 2008;43(10):1853-7. Not eligible target population. [pmid: 18926220].
797 Beeton S. How foot and mouth disease affected a rural continence service. Nurs Times. Oct. 4–10. 2001;97(40):59-60. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11949364].
798 Beguin AM, Combes T, Lutzler P, et al. Health education improves older subjects’ attitudes toward urinary incontinence and access to care: a randomized study in sheltered accommodation centers for the aged. J Am Geriatr Soc. Mar. 1997;45(3):391-2. Not eligible target population. [pmid: 9063297].
799 Beitz JM. Advanced practice nursing: wound, ostomy, continence: a role for the new century. Pa Nurse. Mar. 2006;61(1):22. Not eligible target population. [pmid: 16625771].
800 Beitz JM, Zuzelo PR. The lived experience of having a neobladder. West J Nurs Res. Apr. 2003;25(3):294-316. discussion 7–21. Not eligible target population. [pmid: 12705113].
801 Beji NK, Yalcin O, Erkan HA. The effect of pelvic floor training on sexual function of treated patients. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2003;14(4):234-8. discussion 8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14530833].
802 Bellina M, Mari M, Ambu A, et al. Seminal monolateral nerve-sparing radical prostatectomy in selected patients. Urol Int. 2005;75(2):175-80. Not eligible target population. [pmid: 16123574].
803 Belloli G, Campobasso P, Mercurella A. Neuropathic urinary incontinence in pediatric patients: management with artificial sphincter. J Pediatr Surg. Nov. 1992;27(11):1461-4. Not eligible target population. [pmid: 1479510].
804 Bender CM, Engberg SJ, Donovan HS, et al. Symptom clusters in adults with chronic health problems and cancer as a comorbidity. Oncol Nurs Forum. Jan. 2008;35(1):E1-11. Not eligible target population. [pmid: 18192145].
805 Benderev TV. Anchor fixation and other modifications of endoscopic bladder neck suspension. Urology. Nov. 1992;40(5):409-18. Not eligible exposure. [pmid: 1441037].
806 Bennett RG, Baran PJ, DeVone LV, et al. Low airloss hydrotherapy versus standard care for incontinent hospitalized patients. J Am Geriatr Soc. May. 1998;46(5):569-76. Not eligible population. [pmid: 9588369].
807 Bent AE, Foote J, Siegel S, et al. Collagen implant for treating stress urinary incontinence in women with urethral hypermobility. J Urol. Oct. 2001;166(4):1354-7. Not eligible exposure. [pmid: 11547073].
808 Bent AE, Tutrone RT, McLennan MT, et al. Treatment of intrinsic sphincter deficiency using autologous ear chondrocytes as a bulking agent. Neurourol Urodyn. 2001;20(2):157-65. Not eligible exposure. [pmid: 11170190].
809 Bentas W, Wolfram M, Jones J, et al. Robotic technology and the translation of open radical prostatectomy to laparoscopy: the early Frankfurt experience with robotic radical prostatectomy and one year follow-up. Eur Urol. Aug. 2003;44(2):175-81. Not eligible target population. [pmid: 12875935].
810 Berger M, Wagner TH, Baker LC. Internet use and stigmatized illness. Soc Sci Med. Oct. 2005;61(8):1821-7. Not eligible target population. [pmid: 16029778].
811 Bergert FW, Conrad D, Ehrenthal K, et al. Pharmacotherapy guidelines for the aged by family doctors for the use of family doctors: part C--Special pharmacology. Int J Clin Pharmacol Ther. Mar. 2009;47(3):141-52. Not eligible exposure. [pmid: 19281722].
812 Berglund AL, Eisemann M, Lalos A, et al. Predictive factors of the outcome of primary surgical treatment of stress incontinence in women. Scand J Urol Nephrol. Feb. 1997;31(1):49-55. Not eligible exposure. [pmid: 9060084].
813 Berglund AL, Lalos O. The pre- and postsurgical nursing of women with stress incontinence. J Adv Nurs. Mar. 1996;23(3):502-11. Not eligible exposure. [pmid: 8655825].
814 Bergman A, Elia G. Three surgical procedures for genuine stress incontinence: five-year follow-up of a prospective randomized study. Am J Obstet Gynecol. Jul. 1995;173(1):66-71. Not eligible exposure. [pmid: 7631729].
815 Bergman A, Karram MM, Bhatia NN. Changes in urethral cytology following estrogen administration. Gynecol Obstet Invest. 1990;29(3):211-3. Case-series. [pmid: 2358196].
816 Bergman A, McCarthy TA, Ballard CA, et al. Role of the Q-tip test in evaluating stress urinary incontinence. J Reprod Med. Apr. 1987;32(4):273-5. Not eligible exposure. [pmid: 3585870].
817 Berlowitz DR, Brandeis GH, Morris JN, et al. Deriving a risk-adjustment model for pressure ulcer development using the Minimum Data Set. J Am Geriatr Soc. Jul. 2001;49(7):866-71. Not eligible target population. [pmid: 11527476].
818 Berlowitz DR, Young GJ, Hickey EC, et al. Clinical practice guidelines in the nursing home. Am J Med Qual. Nov–Dec. 2001;16(6):189-95. Not eligible target population. [pmid: 11816849].
819 Berman CJ, Kreder KJ. Comparative cost analysis of collagen injection and fascia lata sling cystourethropexy for the treatment of type III incontinence in women [ssee comments]. J Urol. Jan. 1997;157(1):122-4. Not eligible exposure. [pmid: 8976231].
820 Berry T, Tepera C, Staneck D, et al. Is there correlation of nerve-sparing status and return to baseline urinary function after robot-assisted laparoscopic radical prostatectomy?. J Endourol. Mar. 2009;23(3):489-93. Not eligible target population. [pmid: 19265472].
821 Bertaccini A, Vassallo F, Martino F, et al. Symptoms, bothersomeness and quality of life in patients with LUTS suggestive of BPH. Eur Urol. 2001;40(Suppl 1):13-8. Not eligible target population. [pmid: 11598348].
822 Berthier A, Sentilhes L, Taibi S, et al. Sexual function in women following the transvaginal tension-free tape procedure for incontinence. Int J Gynaecol Obstet. Aug. 2008;102(2):105-9. Not eligible exposure. [pmid: 18420207].
823 Bestmann B, Loetters C, Diemer T, et al. Prostate-specific symptoms of prostate cancer in a German general population. Prostate Cancer Prostatic Dis. 2007;10(1):52-9. Not eligible target population. [pmid: 17102801].
824 Bewley S, Cockburn J. II. The unfacts of ‘request’ caesarean section. BJOG. Jun. 2002;109(6):597-605. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12118634].
825 Bezerra CA, Bruschini H. Suburethral sling operations for urinary incontinence in women. Cochrane Database Syst Rev. 2000;(3):CD001754. Not eligible exposure. [pmid: 10908509].
826 Bezerra CA, Bruschini H. Suburethral sling operations for urinary incontinence in women. Cochrane Database Syst Rev. 2001;(3):CD001754. Not eligible exposure. [pmid: 11686996].
827 Bezerra CA, Bruschini H, Cody DJ. Traditional suburethral sling operations for urinary incontinence in women. Cochrane Database Syst Rev. 2005;(3):CD001754. Not eligible exposure. [pmid: 16034866].
828 Bhandari H, Li K, Tincello D. Maximum bladder volume as surrogate screening test for detrusor overactivity. Paper presented at: Neurourology and Urodynamics, 2010; Joint Meeting of the International Continence Society and the International Urogynecological Association. Toronto, Canada. 23–27 August 2010. Not eligible outcomes.
829 Bharucha AE, Ravi K, Zinsmeister AR. Comparison of selective M3 and nonselective muscarinic receptor antagonists on gastrointestinal transit and bowel habits in humans. Am J Physiol Gastrointest Liver Physiol. Jul. 2010;299(1):G215-9. Not eligible target population. [pmid: 20395537].
830 Bhattacharya S, Mollison J, Pinion S, et al. A comparison of bladder and ovarian function two years following hysterectomy or endometrial ablation. Br J Obstet Gynaecol. Sep. 1996;103(9):898-903. Not eligible target population. [pmid: 8813310].
831 Bhojani N, Perrotte P, Jeldres C, et al. The effect of comorbidities and socioeconomic status on sexual and urinary function in men undergoing prostate cancer screening. J Sex Med. Mar. 2008;5(3):668-76. Not eligible target population. [pmid: 18221289].
832 Bianco FJ Jr, Riedel ER, Begg CB, et al. Variations among high volume surgeons in the rate of complications after radical prostatectomy: further evidence that technique matters. J Urol. Jun. 2005;173(6):2099-103. Not eligible target population. [pmid: 15879851].
833 Bidmead J, Cardozo L, McLellan A, et al. A comparison of the objective and subjective outcomes of colposuspension for stress incontinence in women. BJOG. Apr. 2001;108(4):408-13. Not eligible exposure. [pmid: 11305549].
834 Bignell V. Alleviating the distress of urinary incontinence. Community Nurse. Oct. 1999;5(9):19-20. 2. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10732570].
835 Birnbaum H, Leong S, Kabra A. Lifetime medical costs for women: cardiovascular disease, diabetes, and stress urinary incontinence. Womens Health Issues. Nov–Dec. 2003;13(6):204-13. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14675789].
836 Birnbaum HG, Leong SA, Oster EF, et al. Cost of stress urinary incontinence: a claims data analysis. Pharmacoeconomics. 2004;22(2):95-105. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14731051].
837 Bishoff JT, Motley G, Optenberg SA, et al. Incidence of fecal and urinary incontinence following radical perineal and retropubic prostatectomy in a national population. J Urol. Aug. 1998;160(2):454-8. Not eligible target population. [pmid: 9679897].
838 Bishop KR, Dougherty M, Mooney R, et al. Effects of age, parity, and adherence on pelvic muscle response to exercise. J Obstet Gynecol Neonatal Nurs. Sep–Oct. 1992;21(5):401-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 1403226].
839 Bishop M. A wee problem. Nurs Stand. Nov 30-Dec 6. 2005;20(12):20-1. Comment. [pmid: 16350494].
840 Bjelic-Radisic V, Dorfer M, Greimel E, et al. Quality of life and continence 1 year after the tension-free vaginal tape operation. Am J Obstet Gynecol. Dec. 2006;195(6):1784-8. Not eligible exposure. [pmid: 17132481].
841 Bjelic-Radisic V, Dorfer M, Tamussino K, et al. Psychometric properties and validation of the German-language King’s Health Questionnaire in women with stress urinary incontinence. Neurourol Urodyn. 2005;24(1):63-8. no associative hypothesis tested. [pmid: 15578627].
842 Bjornsdottir LT, Geirsson RT, Jonsson PV. Urinary incontinence and urinary tract infections in octogenarian women. Acta Obstet Gynecol Scand. Jan. 1998;77(1):105-9. Not eligible target population. [pmid: 9492729].
843 Black N, Griffiths J, Pope C, et al. Impact of surgery for stress incontinence on morbidity: cohort study. BMJ. Dec. 6. 1997;315(7121):1493-8. Not eligible exposure. [pmid: 9420489].
844 Black NA, Bowling A, Griffiths JM, et al. Impact of surgery for stress incontinence on the social lives of women. Br J Obstet Gynaecol. Jun. 1998;105(6):605-12. Not eligible exposure. [pmid: 9647150].
845 Black NA, Griffiths JM, Pope C, et al. Sociodemographic and symptomatic characteristics of women undergoing stress incontinence surgery in the UK. Br J Urol. Dec. 1996;78(6):847-55. Not eligible target population. [pmid: 9014707].
846 Blaivas JG. Outcome measures for urinary incontinence. Urology. Feb. 1998;51(2A Suppl):11-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9495729].
847 Blakeman PJ, Hilton P, Bulmer JN. Oestrogen and progesterone receptor expression in the female lower urinary tract, with reference to oestrogen status. BJU Int. Jul. 2000;86(1):32-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10886079].
848 Bland DR, Dugan E, Cohen SJ, et al. The effects of implementation of the Agency for Health Care Policy and Research urinary incontinence guidelines in primary care practices. J Am Geriatr Soc. Jul. 2003;51(7):979-84. no associative hypothesis tested. [pmid: 12834518].
849 Blanes L, de Pinto RC, Santos VL. Urinary incontinence knowledge and attitudes in Sao Paulo. Ostomy Wound Manage. Dec. 2001;47(12):43-51. not eligible outcomes. [pmid: 11889727].
850 Blonski J. Is tolterodine (Detrol) or oxybutynin (Ditropan) the best for treatment of urge urinary incontinence?. J Fam Pract. Dec. 2001;50(12):1017. Comment. [pmid: 11742595].
851 Bluestein D, Rutledge CM. Perceived health and geriatric risk stratification: observations from family practice. Can Fam Physician. May. 2006;52:626-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17327894].
852 Bo K. Adherence to pelvic floor muscle exercise and long-term effect on stress urinary incontinence. A five-year follow-up study. Scand J Med Sci Sports. Feb. 1995;5(1):36-9. Case-series. [pmid: 7882126].
853 Bo K. Effect of electrical stimulation on stress and urge urinary incontinence. Clinical outcome and practical recommendations based on randomized controlled trials. Acta Obstet Gynecol Scand Suppl. 1998;168:3-11. Not eligible review. [pmid: 9744782].
854 Bo K, Maanum M. Does vaginal electrical stimulation cause pelvic floor muscle contraction? A pilot study. Scand J Urol Nephrol Suppl. 1996;179:39-45. Not eligible outcomes. [pmid: 8908663].
855 Bo K, Talseth T. Long-term effect of pelvic floor muscle exercise 5 years after cessation of organized training. Obstet Gynecol. Feb. 1996;87(2):261-5. Case-series. [pmid: 8559536].
856 Boccasanta P, Venturi M, Salamina G, et al. New trends in the surgical treatment of outlet obstruction: clinical and functional results of two novel transanal stapled techniques from a randomised controlled trial. International journal of colorectal disease. 2004:359-69. Not eligible exposure. [pmid: 15024596].
857 Bodell DM, Leach GE. Needle suspension procedures for female incontinence. Urol Clin North Am. Aug. 2002;29(3):575-84. Not eligible exposure. [pmid: 12476521].
858 Boemers TM. Urinary incontinence and vesicourethral dysfunction in pediatric surgical conditions. Semin Pediatr Surg. May. 2002;11(2):91-9. Not eligible target population. [pmid: 11973761].
859 Bogner HR, Gallo JJ, Swartz KL, et al. Anxiety disorders and disability secondary to urinary incontinence among adults over age 50. Int J Psychiatry Med. 2002;32(2):141-54. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12269595].
860 Bogren MA, Hvarfwen E, Fridlund B. Urinary incontinence among a 65-year old Swedish population: medical history and psychosocial consequences. Vard Nord Utveckl Forsk. Winter. 1997;17(4):14-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9464154].
861 Bolduc S, Upadhyay J, Payton J, et al. The use of tolterodine in children after oxybutynin failure. BJU Int. Mar. 2003;91(4):398-401. Not eligible target population. [pmid: 12603422].
862 Bombier L, Freeman RM, Perkins EP, et al. Why do women have voiding dysfunction and de novo detrusor instability after colposuspension?. BJOG. Apr. 2002;109(4):402-12. Not eligible exposure. [pmid: 12013161].
863 Bonetti TR, Erpelding A, Pathak LR. Listening to “felt needs”: investigating genital prolapse in western Nepal. Reprod Health Matters. May. 2004;12(23):166-75. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15242225].
864 Boone TB, Roehrborn CG, Hurt G. Transurethral intravesical electrotherapy for neurogenic bladder dysfunction in children with myelodysplasia: a prospective, randomized clinical trial. J Urol. Aug. 1992;148(2 Pt 2):550-4. Not eligible target population. [pmid: 1640520].
865 Borawski KM, Grafstein NH, Webster GD. Management of Large Volume Post Prostatectomy Urinary Incontinence using a Single Cuff Artificial Urinary Sphincter. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Not eligible target population.
866 Borchers H, Kirschner-Hermanns R, Brehmer B, et al. Permanent 125I-seed brachytherapy or radical prostatectomy: a prospective comparison considering oncological and quality of life results. BJU Int. Oct. 2004;94(6):805-11. Not eligible target population. [pmid: 15476513].
867 Bordman R, Telner D, Jackson B, et al. Step-by-step approach to managing pelvic organ prolapse: information for physicians. Can Fam Physician. Mar. 2007;53(3):485-7. Not eligible exposure. [pmid: 17872686].
868 Borello-France DF, Handa VL, Brown MB, et al. Pelvic-floor muscle function in women with pelvic organ prolapse. Phys Ther. Apr. 2007;87(4):399-407. Not eligible outcomes. [pmid: 17341510].
869 Borrie MJ, Valiquette L. Managing adults with urinary incontinence. Clinical practice guidelines. Can Fam Physician. Jan. 2002;48:114-6. guidelines. [pmid: 11852599].
870 Borstad E, Abdelnoor M, Staff AC, et al. Surgical strategies for women with pelvic organ prolapse and urinary stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2010;21(2):179-86. Not eligible exposure. [pmid: 19940978].
871 Bosman G, Vierhout ME, Huikeshoven FJ. A modified Raz bladder neck suspension operation. Results of a one to three years follow-up investigation. Acta Obstet Gynecol Scand. Jan. 1993;72(1):47-9. Not eligible exposure. [pmid: 8382433].
872 Bossema E, Stiggelbout A, Baas-Thijssen M, et al. Patients’ preferences for low rectal cancer surgery. Eur J Surg Oncol. Jan. 2008;34(1):42-8. Not eligible target population. [pmid: 17905562].
873 Botros SM, Abramov Y, Miller JJ, et al. Effect of parity on sexual function: an identical twin study. Obstet Gynecol. Apr. 2006;107(4):765-70. Not eligible target population. [pmid: 16582110].
874 Boulet MJ, Oddens BJ, Lehert P, et al. Climacteric and menopause in seven South-east Asian countries. Maturitas. Oct. 1994;19(3):157-76. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7799822].
875 Bovbjerg VE, Trowbridge ER, Barber MD, et al. Patient-centered treatment goals for pelvic floor disorders: association with quality-of-life and patient satisfaction. Am J Obstet Gynecol. May. 2009;200(5):568 e1-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 19236871].
876 Bower WF. Self-reported effect of childhood incontinence on quality of life. J Wound Ostomy Continence Nurs. Nov–Dec. 2008;35(6):617-21. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 19018203].
877 Bowles J, Brooks T, Hayes-Reams P, et al. Frailty, family, and church support among urban African American elderly. J Health Care Poor Underserved. Feb. 2000;11(1):87-99. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10778045].
878 Boyd BG, McCallum SW, Lewis RW, et al. Assessment of patient concern and adequacy of informed consent regarding infertility resulting from prostate cancer treatment. Urology. Oct. 2006;68(4):840-4. Not eligible target population. [pmid: 17070364].
879 Boyd SD, Lieskovsky G, Skinner DG. Kock pouch bladder replacement. Urol Clin North Am. Nov. 1991;18(4):641-8. Not eligible target population. [pmid: 1949397].
880 Boyington AR, Wildemuth BM, Dougherty MC, et al. Development of a computer-based system for continence health promotion. Nurs Outlook. Sep–Oct. 2004;52(5):241-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15499313].
881 Boyle DJ, Prosser K, Allison ME, et al. Percutaneous tibial nerve stimulation for the treatment of urge fecal incontinence. Dis Colon Rectum. Apr. 2010;53(4):432-7. Not eligible target population. [pmid: 20305443].
882 Boyle P, Robertson C, Mazzetta C, et al. The prevalence of male urinary incontinence in four centres: the UREPIK study. BJU Int. Dec. 2003;92(9):943-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14632852].
883 Boyles SH, Weber AM, Meyn L. Procedures for pelvic organ prolapse in the United States, 1979–1997. Am J Obstet Gynecol. Jan. 2003;188(1):108-15. Not eligible exposure. [pmid: 12548203].
884 Bradley CS, Arya LA, Rovner ES, et al. Questionnaire for female urinary incontinence diagnosis (QUID): Diagnostic accuracy compared to clinical assessment. Paper presented at: 23rd Annual Meeting of the American Urogynecologic Society. San Fracisco, CA (USA). 17–19 Oct 2002. (World Meeting Number 000 6467). Not eligible outcomes.
885 Bradley CS, Kenton KS, Richter HE, et al. Obesity and outcomes after sacrocolpopexy. Am J Obstet Gynecol. Dec. 2008;199(6):690 e1-8. Not eligible exposure. [pmid: 18845288].
886 Bradley EB, Bissonette EA, Theodorescu D. Determinants of long-term quality of life and voiding function of patients treated with radical prostatectomy or permanent brachytherapy for prostate cancer. BJU Int. Nov. 2004;94(7):1003-9. Not eligible target population. [pmid: 15541117].
887 Bradway C. Women’s narratives of long-term urinary incontinence. Urol Nurs. Oct. 2005;25(5):337-44. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16294611].
888 Bradway C, Coyne KS, Irwin D, et al. Lower urinary tract symptoms in women-a common but neglected problem. J Am Acad Nurse Pract. Jun. 2008;20(6):311-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18588658].
889 Bradway C, Strumpf N. Seeking care: women’s narratives concerning long-term urinary incontinence. Urol Nurs. Apr. 2008;28(2):123-9. Not eligible target population. [pmid: 18488588].
890 Bradway CW, Barg F. Developing a cultural model for long-term female urinary incontinence. Soc Sci Med. Dec. 2006;63(12):3150-61. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16996186].
891 Brady CM, Apostolidis AN, Harper M, et al. Parallel changes in bladder suburothelial vanilloid receptor TRPV1 and pan-neuronal marker PGP9.5 immunoreactivity in patients with neurogenic detrusor overactivity after intravesical resiniferatoxin treatment. BJU Int. Apr. 2004;93(6):770-6. Not eligible outcomes. [pmid: 15049988].
892 Brady L. Prompted voiding yields results. CNAs are key to the success of a pilot study that reduced urinary incontinence for residents of one Illinois facility. Provider. Mar. 2009;35(3):41-4. Not eligible target population. [pmid: 19326800].
893 Braekken IH, Majida M, Engh ME, et al. Can pelvic floor muscle training reverse pelvic organ prolapse and reduce prolapse symptoms? An assessor-blinded, randomized, controlled trial. Am J Obstet Gynecol. Aug. 2010;203(2):170 e1-7. Not eligible target population. [pmid: 20435294].
894 Branch LG, Walker LA, Wetle TT, et al. Urinary incontinence knowledge among community-dwelling people 65 years of age and older. J Am Geriatr Soc. Dec. 1994;42(12):1257-62. Not eligible exposure. [pmid: 7983288].
895 Braslis KG, Santa-Cruz C, Brickman AL, et al. Quality of life 12 months after radical prostatectomy. Br J Urol. Jan. 1995;75(1):48-53. Not eligible target population. [pmid: 7850295].
896 Brazier AM. Assessment of urinary incontinence in nursing homes: level 2. Nurse Pract Forum. Sep. 1994;5(3):158-62. Not eligible target population. [pmid: 7950495].
897 Brazier J, Czoski-Murray C, Roberts J, et al. Estimation of a preference-based index from a condition-specific measure: the King’s Health Questionnaire. Med Decis Making. Jan–Feb. 2008;28(1):113-26. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17641139].
898 Brendler C, Schlegel P, Dowd J, et al. Surgical treatment for benign prostatic hyperplasia. Cancer. Jul. 1. 1992;70(1 Suppl):371-3. Not eligible target population. [pmid: 1376210].
899 Brennan ML, Evans A. Why catheterize?: audit findings on the use of urinary catheters. Br J Nurs. May. 10–23. 2001;10(9):580-90. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12066031].
900 Brenner B, Rice M. Patients with overactive bladders deserve better. N Z Med J. 2006;119(1229):U1846. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16498474].
901 Brett TD. Patients’ attitudes to prostate cancer. Aust Fam Physician. Jul. 1998;27(Suppl 2):S84-8. Not eligible target population. [pmid: 9679361].
902 Breza J, Hornak M, Bardos A, et al. Transformation of the Bricker to a continent urinary reservoir to eliminate severe complications of uretero-ileostomy performed in eight patients among 200 Bricker. Ann Urol (Paris). 1995;29(4):227-31. Not eligible target population. [pmid: 8554293].
903 Brink CA, Wells TJ, Sampselle CM, et al. A digital test for pelvic muscle strength in women with urinary incontinence. Nurs Res. Nov–Dec. 1994;43(6):352-6. Not eligible exposure. [pmid: 7971299].
904 Brittain K. Stroke and continence care. Nurs Times. Jul 26-Aug 1. 2001;97(30):57. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11957960].
905 Brittain KR, Shaw C. The social consequences of living with and dealing with incontinence--a carers perspective. Soc Sci Med. Sep. 2007;65(6):1274-83. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17509743].
906 Britton B. Continence. Marketing forces. Nurs Times. Aug. 7–13. 1991;87(33):68. 70. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 1871022].
907 Brocklehurst JC. Urinary incontinence in the community--analysis of a MORI poll. BMJ. Mar. 27. 1993;306(6881):832-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8490377].
908 Brodie A. A guide to the management of one-piece urinary sheaths. Nurs Times. Feb 28-Mar 6. 2006;102(9):49-51. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16539324].
909 Brooks V. Treat incontinence early. Nurs Stand. May. 1–7. 2002;16(33):22. Not eligible target population. [pmid: 12035302].
910 Broome BA. Development and testing of a scale to measure self-efficacy for pelvic muscle exercises in women with urinary incontinence. Urol Nurs. Dec. 1999;19(4):258-68. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10889770].
911 Broome BA. Psychometric analysis of the Broome Pelvic Muscle Self-Efficacy Scale in African-American women with incontinence. Urol Nurs. Aug. 2001;21(4):289-97. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11998458].
912 Brown AF, M CM, S D, S CA. CHFAGSPoICfEwD. Guidelines for improving the care of the older person with diabetes mellitus. Journal of the American Geriatrics Society. May. 2003;51(5 Suppl Guidelines):S265-80. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12694461].
913 Brown JA, Elliott DS, Barrett DM. Postprostatectomy urinary incontinence: a comparison of the cost of conservative versus surgical management. Urology. May. 1998;51(5):715-20. Not eligible target population. [pmid: 9610584].
914 Brown JS. Epidemiology and changing demographics of overactive bladder: a focus on the postmenopausal woman. Geriatrics. May. 2002;57(Suppl 1):6-12. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12040602].
915 Brown JS, Grady D, Ouslander JG, et al. Prevalence of urinary incontinence and associated risk factors in postmenopausal women. Heart & Estrogen/Progestin Replacement Study (HERS) Research Group. Obstet Gynecol. Jul. 1999;94(1):66-70. Not eligible exposure. [pmid: 10389720].
916 Brown JS, Posner SF, Stewart AL. Urge incontinence: new health-related quality of life measures. J Am Geriatr Soc. Aug. 1999;47(8):980-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10443860].
917 Brown JS, Subak LL, Gras J, et al. Urge incontinence: the patient’s perspective. J Womens Health. Dec. 1998;7(10):1263-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9929859].
918 Brown JS, Vittinghoff E, Kanaya AM, et al. Urinary tract infections in postmenopausal women: effect of hormone therapy and risk factors. Obstet Gynecol. Dec. 2001;98(6):1045-52. Not eligible population. [pmid: 11755552].
919 Brown JS, Vittinghoff E, Lin F, et al. Prevalence and risk factors for urinary incontinence in women with type 2 diabetes and impaired fasting glucose: findings from the National Health and Nutrition Examination Survey (NHANES) 2001–2002. Diabetes Care. Jun. 2006;29(6):1307-12. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16732013].
920 Brown S, Lumley J. Maternal health after childbirth: results of an Australian population based survey. Br J Obstet Gynaecol. Feb. 1998;105(2):156-61. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9501779].
921 Brown SL, Govier FE. Cadaveric versus autologous fascia lata for the pubovaginal sling: surgical outcome and patient satisfaction. J Urol. Nov. 2000;164(5):1633-7. Not eligible exposure. [pmid: 11025722].
922 Browning A. Prevention of residual urinary incontinence following successful repair of obstetric vesico-vaginal fistula using a fibro-muscular sling. BJOG. Apr. 2004;111(4):357-61. Not eligible exposure. [pmid: 15008773].
923 Browning A, Menber B. Women with obstetric fistula in Ethiopia: a 6-month follow up after surgical treatment. BJOG. Nov. 2008;115(12):1564-9. Not eligible exposure. [pmid: 19035992].
924 Brubaker L. Clinical advances in urogynecology. Minerva Ginecol. Aug. 2006;58(4):259-64. no associated hypothesis tested. [pmid: 16957670].
925 Brubaker L, Chiang S, Zyczynski H, et al. The impact of stress incontinence surgery on female sexual function. Am J Obstet Gynecol. May. 2009;200(5):562 e1-7. Not eligible exposure. [pmid: 19286143].
926 Brubaker L, Cundiff G, Fine P, et al. A randomized trial of colpopexy and urinary reduction efforts (CARE): design and methods. Control Clin Trials. Oct. 2003;24(5):629-42. Not eligible exposure. [pmid: 14500059].
927 Brubaker L, Cundiff GW, Fine P, et al. Abdominal sacrocolpopexy with Burch colposuspension to reduce urinary stress incontinence. N Engl J Med. Apr. 13. 2006;354(15):1557-66. Not eligible exposure. [pmid: 16611949].
928 Brubaker L, Nygaard I, Richter HE, et al. Two-year outcomes after sacrocolpopexy with and without burch to prevent stress urinary incontinence. Obstetrics & Gynecology. Jul. 2008;112(1):49-55. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18591307].
929 Brunenberg DE, Joore MA, Veraart CP, et al. Economic evaluation of duloxetine for the treatment of women with stress urinary incontinence: a Markov model comparing pharmacotherapy with pelvic floor muscle training. Clin Ther. Apr. 2006;28(4):604-18. Secondary data analysis. [pmid: 16750472].
930 Bruner DW, Hanlon A, Mazzoni S, et al. Predictors of preferences and utilities in men treated with 3D-CRT for prostate cancer. Int J Radiat Oncol Biol Phys. Jan. 1. 2004;58(1):34-42. Not eligible target population. [pmid: 14697418].
931 Bucci AT. Be a continence champion: use the CHAMMP tool to individualize the plan of care. Geriatric nursing. quiz 125. Mar–Apr. 2007;28(2):120-4. Comment. [pmid: 17430746].
932 Buchanan RJ, Choi M, Wang S, et al. Analyses of nursing home residents in hospice care using the minimum data set. Palliat Med. Nov. 2002;16(6):465-80. Not eligible target population. [pmid: 12465693].
933 Buchanan RJ, Wang S, Huang C, et al. Profiles of nursing home residents with multiple sclerosis using the minimum data set. Mult Scler. Jun. 2001;7(3):189-200. Not eligible target population. [pmid: 11475444].
934 Buchanan RJ, Wang S, Huang C, et al. Analyses of nursing home residents with Parkinson’s disease using the minimum data set. Parkinsonism Relat Disord. Jun. 2002;8(5):369-80. Not eligible target population. [pmid: 15177067].
935 Buchsbaum GM, McConville J, Korni R, et al. Outcome of transvaginal radiofrequency for treatment of women with stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Mar. 2007;18(3):263-5. Not eligible exposure. [pmid: 16788852].
936 Buckley BS, Lapitan MC. Prevalence of urinary and faecal incontinence and nocturnal enuresis and attitudes to treatment and help-seeking amongst a community-based representative sample of adults in the United Kingdom. Int J Clin Pract. Apr. 2009;63(4):568-73. Not eligible outcomes. [pmid: 19175680].
937 Bug GJ, Kiff ES, Hosker G. A new condition-specific health-related quality of life questionnaire for the assessment of women with anal incontinence. BJOG. Oct. 2001;108(10):1057-67. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11702838].
938 Bugg GJ, Hosker GL, Kiff ES. Routine symptom screening for postnatal urinary and anal incontinence in new mothers from a district. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2005;16(5):405-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15891806].
939 Bukkapatnam R, Shah S, Raz S, et al. Anterior vaginal wall surgery in elderly patients: outcomes and assessment. Urology. Jun. 2005;65(6):1104-8. Not eligible exposure. [pmid: 15953501].
940 Bull E, Chilton CP, Gould CA, et al. Single-blind, randomised, parallel group study of the Bard Biocath catheter and a silicone elastomer coated catheter. Br J Urol. Oct. 1991;68(4):394-9. Not eligible exposure. [pmid: 1933160].
941 Bulmer PJ, James M, Ellis-Jones J, et al. A randomized trial comparing the effectiveness and preference of a touch-screen computer system with a leaflet for providing women with information on urinary symptoms suggestive of detrusor instability. BJU Int. Oct. 2001;88(6):532-5. Not eligible outcomes. [pmid: 11678745].
942 Bump RC, Hurt WG, Fantl JA, et al. Assessment of Kegel pelvic muscle exercise performance after brief verbal instruction. Am J Obstet Gynecol. Aug. 1991;165(2):322-7. discussion 7–9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 1872333].
943 Bump RC, Hurt WG, Theofrastous JP, et al. Randomized prospective comparison of needle colposuspension versus endopelvic fascia plication for potential stress incontinence prophylaxis in women undergoing vaginal reconstruction for stage III or IV pelvic organ prolapse. The Continence Program for Women Research Group. Am J Obstet Gynecol. Aug. 1996;175(2):326-33. discussion 33–5. Not eligible exposure. [pmid: 8765249].
944 Bump RC, McClish DM. Cigarette smoking and pure genuine stress incontinence of urine: a comparison of risk factors and determinants between smokers and nonsmokers. Am J Obstet Gynecol. Feb. 1994;170(2):579-82. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8116716].
945 Bunyavejchevin S. Urinary symptoms and quality of life changes in Thai women with overactive bladder after tolterodine treatment. J Med Assoc Thai. Nov. 2005;88(11):1497-501. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16471092].
946 Bunyavejchevin S. The impact of overactive bladder, stress and mixed urinary incontinence on quality of life in Thai postmenopausal women. J Med Assoc Thai. Mar. 2006;89(3):294-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16696411].
947 Bunyavejchevin S, Veeranarapanich S. Quality of life assessment in Thai postmenopausal women with an overactive bladder. J Med Assoc Thai. Aug. 2005;88(8):1023-7. Not eligible target population. [pmid: 16404827].
948 Burgio KL. Behavioral Treatment Options for Urinary Incontinence. Gastroenterology. 2004;126(1). Review. [pmid: 14978643].
949 Burgio KL, Goode PS, Locher JL, et al. Predictors of outcome in the behavioral treatment of urinary incontinence in women. Obstet Gynecol. Nov. 2003;102(5 Pt 1):940-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14672467].
950 Burgio KL, Goode PS, Urban DA, et al. Preoperative biofeedback assisted behavioral training to decrease post-prostatectomy incontinence: a randomized, controlled trial. J Urol. Jan. 2006;175(1):196-201. discussion 16406909. Not eligible target population. [pmid: 16406909].
951 Burgio KL, Ives DG, Locher JL, et al. Treatment seeking for urinary incontinence in older adults. J Am Geriatr Soc. Feb. 1994;42(2):208-12. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8126338].
952 Burgio KL, Locher JL, Zyczynski H, et al. Urinary incontinence during pregnancy in a racially mixed sample: characteristics and predisposing factors. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(2):69-73. Not eligible exposure. [pmid: 8798089].
953 Burgio KL, Nygaard IE, Richter HE, et al. Bladder symptoms 1 year after abdominal sacrocolpopexy with and without Burch colposuspension in women without preoperative stress incontinence symptoms. Am J Obstet Gynecol. Dec. 2007;197(6):647 e1-6. Not eligible exposure. [pmid: 18060965].
954 Burgio KL, Robinson JC, Engel BT. The role of biofeedback in Kegel exercise training for stress urinary incontinence. Am J Obstet Gynecol. Jan. 1986;154(1):58-64. Not eligible level of evidence. [pmid: 3946505].
955 Burgio LD, Engel BT, Hawkins A, et al. A staff management system for maintaining improvements in continence with elderly nursing home residents. J Appl Behav Anal. Spring. 1990;23(1):111-8. Not eligible target population. [pmid: 2335482].
956 Burkhard FC, Heesakkers J. Open to debate. The motion: tapes and not bulking agents/drugs are first-line treatment of SUI. Eur Urol. Sep. 2007;52(3):914-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17604903].
957 Burnet C, Carter H, Gorman D. Urinary incontinence: a survey of knowledge, working practice and training needs of nursing staff in Fife. Health Bull (Edinb). Nov. 1992;50(6):448-52. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 1483871].
958 Burns PA, Nochajski TH, Pranikoff K. Factors discriminating between genuine stress and mixed incontinence. J Am Acad Nurse Pract. Jan–Mar. 1992;4(1):15-21. Not eligible exposure. [pmid: 1605988].
959 Buron C, Le Vu B, Cosset JM, et al. Brachytherapy versus prostatectomy in localized prostate cancer: results of a French multicenter prospective medico-economic study. Int J Radiat Oncol Biol Phys. Mar. 1. 2007;67(3):812-22. Not eligible target population. [pmid: 17293235].
960 Burrows LJ, Meyn LA, Walters MD, et al. Pelvic symptoms in women with pelvic organ prolapse. Obstet Gynecol. Nov. 2004;104(5 Pt 1):982-8. no associative hypothesis tested. [pmid: 15516388].
961 Burt J, Caelli K, Moore K, et al. Radical prostatectomy: men’s experiences and postoperative needs. J Clin Nurs. Aug. 2005;14(7):883-90. Not eligible target population. [pmid: 16000103].
962 Bush TA, Castellucci DT, Phillips C. Exploring women’s beliefs regarding urinary incontinence. Urol Nurs. Jun. 2001;21(3):211-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11998652].
963 But I, Faganelj M. Complications and short-term results of two different transobturator techniques for surgical treatment of women with urinary incontinence: a randomized study. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2008;19(6):857-61. Not eligible exposure. [pmid: 18188489].
964 Butler L, Downe-Wamboldt B, Marsh S, et al. Behind the scenes: partners’ perceptions of quality of life post radical prostatectomy. Urol Nurs. Aug. 2000;20(4):254-8. Not eligible target population. [pmid: 11998088].
965 Butler L, Downe-Wamboldt B, Marsh S, et al. Quality of life post radical prostatectomy: a male perspective. Urol Nurs. Aug. 2001;21(4):283-8. Not eligible target population. [pmid: 11998457].
966 Butler RN, Maby JI, Montella JM, et al. Urinary incontinence: primary care therapies for the older woman. Geriatrics. Nov. 1999;54(11):31-4. 9. 40. 3. 4. no primary result. [pmid: 10570655].
967 Butler RN, Maby JI, Montella JM, et al. Urinary incontinence: keys to diagnosis of the older woman.1. Geriatrics. Oct. 1999;54(10):22-6. 9. 30. No primary result. [pmid: 10542858].
968 Butler WM, Merrick GS, Dorsey AT, et al. Modern prostate brachytherapy. Med Dosim. Fall. 2000;25(3):149-53. Not eligible target population. [pmid: 11025262].
969 Butterfield YC, O’Connell B, Phillips D. Peripartum urinary incontinence: a study of midwives’ knowledge and practices. Women Birth. Jun. 2007;20(2):65-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17499569].
970 Byck DB, Varner RE, Clough C. Urinary complaints after modified Burch urethropexy: an analysis. Am J Obstet Gynecol. Dec. 1994;171(6):1460-2. discussion 2–4. Not eligible exposure. [pmid: 7802054].
971 Byers PH, Ryan PA, Regan MB, et al. Effects of incontinence care cleansing regimens on skin integrity. Journal of wound, ostomy, and continence nursing : official publication of The Wound, Ostomy and Continence Nurses Society / WOCN. 1995:187-92. Not eligible target population.
972 Cain MP, Wu SD, Austin PF, et al. Alpha blocker therapy for children with dysfunctional voiding and urinary retention. J Urol. Oct. 2003;170(4 Pt 2):1514-5. discussion 6–7. Not eligible target population. [pmid: 14501648].
973 Callahan CM. The costs of urinary incontinence. Pharmacoeconomics. Aug. 1994;6(2):183-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10147442].
974 Cam C, Sakalli M, Ay P, et al. Validation of the short forms of the incontinence impact questionnaire (IIQ-7) and the urogenital distress inventory (UDI-6) in a Turkish population. Neurourol Urodyn. 2007;26(1):129-33. Not eligible outcomes. [pmid: 17083117].
975 Cammu H. Female incontinence. Clinical examination by the gynecologist. Acta Urol Belg. May. 1995;63(2):9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7785549].
976 Cammu H, Van Nylen M. Pelvic floor muscle exercises: 5 years later. Urology. Jan. 1995;45(1):113-7. discussion 8. Case-series. [pmid: 7817462].
977 Cammu H, Van Nylen M. Pelvic floor muscle exercises in genuine urinary stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(5):297-300. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9557995].
978 Campbell EB, Knight M, Benson M, et al. Effect of an incontinence training program on nursing home staff’s knowledge, attitudes, and behavior. Gerontologist. Dec. 1991;31(6):788-94. Not eligible target population. [pmid: 1800252].
979 Campbell JM, Dowd TT. Capturing scarce resources: documentation and communication. Nurs Econ. Mar–Apr. 1993;11(2):103-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8502299].
980 Campeau L, Tu LM, Lemieux MC, et al. A multicenter, prospective, randomized clinical trial comparing tension-free vaginal tape surgery and no treatment for the management of stress urinary incontinence in elderly women. Neurourol Urodyn. 2007;26(7):990-4. Not eligible exposure. [pmid: 17638307].
981 Canada H. Product Monograph for BOTOX. Available at: http://webprod.hc-sc.gc.ca/dpd-bdpp/info.do?lang=eng&code=13476. Accessed June 25, 2010. Not eligible treatment.
982 Canada H. Product Monograph for PREMARIN VAGINAL CREAM. Available at: http://webprod.hc-sc.gc.ca/dpd-bdpp/info.do?lang=eng&code=15704. Accessed June 25, 2010. Not eligible treatment.
983 Canada H. Product Monograph for DITROPAN XL -(10MG). Available at: http://webprod.hc-sc.gc.ca/dpd-bdpp/info.do?lang=eng&code=67904. Accessed June 25, 2010. Not eligible treatment.
984 Canada H. Product Monograph for XEOMIN. Available at: http://webprod.hc-sc.gc.ca/dpd-bdpp/info.do?lang=eng&code=80952. Accessed June 25, 2010. Not eligible treatment.
985 Capelini MV, Riccetto CL, Dambros M, et al. Pelvic floor exercises with biofeedback for stress urinary incontinence. Int Braz J Urol. Jul–Aug. 2006;32(4):462-8. discussion 9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16953917].
986 Capitanucci ML, Camanni D, Demelas F, et al. Long-term efficacy of percutaneous tibial nerve stimulation for different types of lower urinary tract dysfunction in children. J Urol. Oct. 2009;182(4 Suppl):2056-61. Not eligible target population. [pmid: 19695611].
987 Caplan GA, Ward JA, Brennan NJ, et al. Hospital in the home: a randomised controlled trial. Med J Aust. Feb. 15. 1999;170(4):156-60. Not eligible target population. [pmid: 10078179].
988 Cappellano F, Bertapelle P, Spinelli M, et al. Quality of life assessment in patients who undergo sacral neuromodulation implantation for urge incontinence: an additional tool for evaluating outcome. J Urol. Dec. 2001;166(6):2277-80. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11696751].
989 Caputo RM, Benson JT, McClellan E. Intravaginal maximal electrical stimulation in the treatment of urinary incontinence. J Reprod Med. Sep. 1993;38(9):667-71. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8254586].
990 Carcio H. The vaginal pessary: an effective yet underused tool for incontinence and prolapse. Adv Nurse Pract. Oct. 2004;12(10):47-8. 50. 2. 4. passim. Comment. [pmid: 15518119].
991 Cardenas DD, Topolski TD, White CJ, et al. Sexual functioning in adolescents and young adults with spina bifida. Arch Phys Med Rehabil. Jan. 2008;89(1):31-5. Not eligible target population. [pmid: 18164327].
992 Cardozo L. New developments in the management of stress urinary incontinence. BJU Int. Jul. 2004;94(Suppl 1):1-3. no primary result. [pmid: 15139856].
993 Cardozo L, Coyne KS, Versi E. Validation of the urgency perception scale. BJU Int. Mar. 2005;95(4):591-6. Not eligible outcomes. [pmid: 15705086].
994 Cardozo L, Dixon A. Increased warning time with darifenacin: a new concept in the management of urinary urgency. J Urol. Apr. 2005;173(4):1214-8. Not eligible population. [pmid: 15758755].
995 Caress JB, Kothari MJ, Bauer SB, et al. Urinary dysfunction in Duchenne muscular dystrophy. Muscle Nerve. Jul. 1996;19(7):819-22. Not eligible target population. [pmid: 8965833].
996 Carey JM, Leach GE. Transvaginal surgery in the octogenarian using cadaveric fascia for pelvic prolapse and stress incontinence: minimal one-year results compared to younger patients. Urology. Apr. 2004;63(4):665-70. Not eligible exposure. [pmid: 15072875].
997 Carey MP, De Jong S, Friedhuber A, et al. A prospective evaluation of the pathogenesis of detrusor instability in women, using electron microscopy and immunohistochemistry. BJU Int. Dec. 2000;86(9):970-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11119088].
998 Carey MP, Goh JT, Rosamilia A, et al. Laparoscopic versus open Burch colposuspension: a randomised controlled trial. BJOG. Sep. 2006;113(9):999-1006. Not eligible exposure. [pmid: 16956331].
999 Carlisle D. Silent suffering. Nurs Times. Apr. 15–21. 1998;94(15):63-4. 7. Not eligible exposure. [pmid: 9615666].
1000 Carls C. The prevalence of stress urinary incontinence in high school and college-age female athletes in the midwest: implications for education and prevention. Urol Nurs. Feb. 2007;27(1):21-4. 39. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17390923].
1001 Caro FG, Glickman LL, Ingegneri D, et al. The impact of the closing of three Massachusetts public chronic disease hospitals: a multidimensional perspective. J Community Health. Jun. 1997;22(3):155-74. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9178116].
1002 Carr LK, Steele D, Steele S, et al. 1-year follow-up of autologous muscle-derived stem cell injection pilot study to treat stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2008;19(6):881-3. Not eligible exposure. [pmid: 18204978].
1003 Carr MC. Conservative nonsurgical management of spina bifida. Curr Urol Rep. Mar. 2010;11(2):109-13. Not eligible target population. [pmid: 20425098].
1004 Carta G, Cerrone L, Iovenitti P. Tension-free vaginal tape procedure for treatment of USI: subjective and objective efficacy evaluation. Clin Exp Obstet Gynecol. 2002;29(4):247-50. Not eligible exposure. [pmid: 12635739].
1005 Cartier C. From home to hospital and back again: economic restructuring, end of life, and the gendered problems of place-switching health services. Soc Sci Med. Jun. 2003;56(11):2289-301. Comment. [pmid: 12719182].
1006 Casale AJ, Metcalfe PD, Kaefer MA, et al. Total continence reconstruction: a comparison to staged reconstruction of neuropathic bowel and bladder. J Urol. Oct. 2006;176(4 Pt 2):1712-5. Not eligible target population. [pmid: 16945629].
1007 Castina S, Boyington A, Dougherty M. Urinary incontinence. Am J Nurs. Aug. 2002;102(8):85-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12394044].
1008 Castro-Gago M, Novo I, Cimadevila A, et al. Management of neurogenic bladder dysfunction secondary to myelomeningocele. Eur J Pediatr. Nov. 1990;150(1):62-5. Not eligible target population. [pmid: 2079080].
1009 Cawello W, Auer S, Hammes W, et al. Multiple does pharmacokinetics of fesoterodine in human subjects [abstract]. Naunyn Schmiedebergs Arch Pharmacol. 2002;365(Suppl 1):428. Not eligible outcomes.
1010 Cayir G, Beji NK, Yalcin O. Effectiveness of nursing care after surgery for stress urinary incontinence. Urol Nurs. Feb. 2007;27(1):25-33. Not eligible exposure. [pmid: 17390924].
1011 Ceresoli A, Zanetti G, Seveso M, et al. Perineal biofeedback versus pelvic floor training in the treatment of urinary incontinence. Archivio Italiano di Urologia, Andrologia. 1993:559-60. Language.
1012 Cespedes RD, Cross CA, McGuire EJ. Pubovaginal fascial slings. Tech Urol. Winter. 1997;3(4):195-201. Not eligible exposure. [pmid: 9531102].
1013 Cetinel B, Demirkesen O, Tarcan T, et al. Hidden female urinary incontinence in urology and obstetrics and gynecology outpatient clinics in Turkey: what are the determinants of bothersome urinary incontinence and help-seeking behavior?. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2007;18(6):659-64. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17164988].
1014 Chadwick V. Assessment of functional incontinence in disabled living centres. Nurs Times. Jan. 11–17. 2005;101(2):65-7. Comment. [pmid: 15688926].
1015 Chai TC, Albo ME, Richter HE, et al. Complications in women undergoing Burch colposuspension versus autologous rectus fascial sling for stress urinary incontinence. J Urol. May. 2009;181(5):2192-7. Not eligible exposure. [pmid: 19296969].
1016 Chaisaeng S, Santingamkun A, Opanuraks J, et al. IQOL: translation & reliability for use with urinary incontinence patients in Thailand. J Med Assoc Thai. Sep. 2006;89(Suppl 3):S33-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17722303].
1017 Chakrabarty A, Hsiao KC, Mulcahy JJ. De Novo Double Cuff Artificial Urinary Sphincter (DCAUS), for Post- Prostatectomy Urinary Incontinence: Long-Term Subjective Results. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Not eligible target population.
1018 Chaliha C, Stanton SL. The ethnic cultural and social aspects of incontinence--a pilot study. International Urogynecology Journal. 1999;10(3):166-70. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 21159].
1019 Chan KM, Pang WS, Ee CH, et al. Functional status of the elderly in Singapore. Singapore Med J. Oct. 1999;40(10):635-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10741191].
1020 Chancellor MB, Bennett C, Simoneau AR, et al. Sphincteric stent versus external sphincterotomy in spinal cord injured men: prospective randomized multicenter trial. J Urol. Jun. 1999;161(6):1893-8. Not eligible target population. [pmid: 10332461].
1021 Chandiramani VA, Palace J, Fowler CJ. How to recognize patients with parkinsonism who should not have urological surgery. Br J Urol. Jul. 1997;80(1):100-4. Not eligible target population. [pmid: 9240187].
1022 Chang CH, Gonzalez CM, Lau DT, et al. Urinary incontinence and self-reported health among the U.S. Medicare managed care beneficiaries. J Aging Health. Jun. 2008;20(4):405-19. Not eligible exposure. [pmid: 18372429].
1023 Chang PL, Tsai LH, Huang ST, et al. The early effect of pelvic floor muscle exercise after transurethral prostatectomy. J Urol. Aug. 1998;160(2):402-5. Not eligible target population. [pmid: 9679887].
1024 Chapple CR, Nilvebrant L. Tolterodine: selectivity for the urinary bladder over the eye (as measured by visual accommodation) in healthy volunteers. Drugs R D. 2002;3(2):75-81. Not eligible target population. [pmid: 12001821].
1025 Chapple CR, Patroneva A, Raines SR. Effect of an ATP-sensitive potassium channel opener in subjects with overactive bladder: a randomized, double-blind, placebo-controlled study (ZD0947IL/0004). Eur Urol. May. 2006;49(5):879-86. Not eligible exposure. [pmid: 16517051].
1026 Chatwin NA, Ribordy M, Givel JC. Clinical outcomes and quality of life after low anterior resection for rectal cancer. Eur J Surg. 2002;168(5):297-301. Not eligible target population. [pmid: 12375612].
1027 Chaussy C, Thuroff S. Results and side effects of high-intensity focused ultrasound in localized prostate cancer. J Endourol. May. 2001;15(4):437-40. discussion 47–8. Not eligible target population. [pmid: 11394458].
1028 Cheater FM. Nurses’ educational preparation and knowledge concerning continence promotion. J Adv Nurs. Mar. 1992;17(3):328-38. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 1573101].
1029 Cheater FM, Baker R, Gillies C, et al. The nature and impact of urinary incontinence experienced by patients receiving community nursing services: a cross-sectional cohort study. Int J Nurs Stud. Mar. 2008;45(3):339-51. Not eligible exposure. [pmid: 17178120].
1030 Chen B, Wen Y, Wang H, et al. Differences in estrogen modulation of tissue inhibitor of matrix metalloproteinase-1 and matrix metalloproteinase-1 expression in cultured fibroblasts from continent and incontinent women. Am J Obstet Gynecol. Jul. 2003;189(1):59-65. Not eligible exposure. [pmid: 12861139].
1031 Chen B, Wen Y, Yu X, et al. Elastin metabolism in pelvic tissues: is it modulated by reproductive hormones?. Am J Obstet Gynecol. May. 2005;192(5):1605-13. Not eligible exposure. [pmid: 15902165].
1032 Chen B, Wen Y, Zhang Z, et al. Menstrual phase-dependent gene expression differences in periurethral vaginal tissue from women with stress incontinence. Am J Obstet Gynecol. Jul. 2003;189(1):89-97. Not eligible exposure. [pmid: 12861144].
1033 Chen CC, Rooney CM, Paraiso MF, et al. Leak point pressure does not correlate with incontinence severity or bother in women undergoing surgery for urodynamic stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2008;19(9):1193-8. Not eligible exposure. [pmid: 18414765].
1034 Chen GD, Lin TL, Hu SW, et al. Prevalence and correlation of urinary incontinence and overactive bladder in Taiwanese women. Neurourol Urodyn. 2003;22(2):109-17. Not eligible target population. [pmid: 12579627].
1035 Chen KK, Chang LS, Chen MT. Neobladder construction using completely detubularized sigmoid colon after radical cystoprostatectomy. J Urol. Aug. 1991;146(2):311-5. Not eligible target population. [pmid: 1856923].
1036 Chen SY. The development and testing of the pelvic floor muscle exercise self-efficacy scale. J Nurs Res. Dec. 2004;12(4):257-66. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15619176].
1037 Chen TY, Ponsot Y, Carmel M, et al. Multi-centre study of intraurethral valve-pump catheter in women with a hypocontractile or acontractile bladder. Eur Urol. Oct. 2005;48(4):628-33. Not eligible target population. [pmid: 15964124].
1038 Chen Y, DeSautel M, Anderson A, et al. Collagen synthesis is not altered in women with stress urinary incontinence. Neurourol Urodyn. 2004;23(4):367-73. Not eligible outcomes. [pmid: 15227656].
1039 Chene G, Amblard J, Tardieu AS, et al. Long-term results of tension-free vaginal tape (TVT) for the treatment of female urinary stress incontinence. Eur J Obstet Gynecol Reprod Biol. Sep. 2007;134(1):87-94. Not eligible exposure. [pmid: 16891051].
1040 Cheng H, Gurland BJ, Maurer MS. Self-reported lack of energy (anergia) among elders in a multiethnic community. J Gerontol A Biol Sci Med Sci. Jul. 2008;63(7):707-14. Not eligible target population. [pmid: 18693225].
1041 Cheon WC, Mak JH, Liu JY. Prospective randomised controlled trial comparing laparoscopic and open colposuspension. Hong Kong Med J. Feb. 2003;9(1):10-4. Not eligible exposure. [pmid: 12547950].
1042 Chess-Williams R, Chapple CR, Yamanishi T, et al. The minor population of M3-receptors mediate contraction of human detrusor muscle in vitro. J Auton Pharmacol. Oct–Dec. 2001;21(5–6):243-8. Not eligible target population. [pmid: 12123469].
1043 Chesterman J, Bauld L, Judge K. Satisfaction with the care-managed support of older people: an empirical analysis. Health Soc Care Community. Jan. 2001;9(1):31-42. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11560719].
1044 Chiaffarino F, Parazzini F, Lavezzari M, et al. Impact of urinary incontinence and overactive bladder on quality of life. Eur Urol. May. 2003;43(5):535-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12705999].
1045 Chiarelli P. Urinary stress incontinence and overactive bladder symptoms in older women. Contemp Nurse. Oct. 2007;26(2):198-207. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18041971].
1046 Chiarelli P, Murphy B, Cockburn J. Acceptability of a urinary continence promotion programme to women in postpartum. BJOG. Feb. 2003;110(2):188-96. Not eligible target population. [pmid: 12618164].
1047 Chien GW, Tawadroas M, Kaptein JS, et al. Surgical treatment for stress urinary incontinence with urethral hypermobility: what is the best approach?. World J Urol. Sep. 2002;20(4):234-9. Not eligible exposure. [pmid: 12215853].
1048 Chin-Peuckert L, Rennick JE, Jednak R, et al. Should warm infusion solution be used for urodynamic studies in children? A prospective randomized study. The Journal of urology. 2004:1657-61. discussion 61. Not eligible target population. [pmid: 15371784].
1049 Chiverton PA, Wells TJ, Brink CA, et al. Psychological factors associated with urinary incontinence. Clin Nurse Spec. Sep. 1996;10(5):229-33. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9069824].
1050 Cho CY, Alessi CA, Cho M, et al. The association between chronic illness and functional change among participants in a comprehensive geriatric assessment program. J Am Geriatr Soc. Jun. 1998;46(6):677-82. Not eligible exposure. [pmid: 9625181].
1051 Choe JM. Preventing urethral obstruction using the 6-point fixation and weight-adjusted spacing nomogram during sling surgery. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(2):122-8. Not eligible exposure. [pmid: 11374510].
1052 Choe JM. Suprapubic sling adjustment: minimally invasive method of curing recurrent stress incontinence after sling surgery. J Urol. Nov. 2002;168(5):2059-62. Not eligible exposure. [pmid: 12394708].
1053 Choe JM. Pubovaginal sling surgery without using abdominal leak point pressure: an outcomes analysis. Adv Exp Med Biol. 2003;539:467-80. Not eligible exposure. [pmid: 15088923].
1054 Choe JM. The use of synthetic materials in pubovaginal sling. Adv Exp Med Biol. 2003;539:481-92. Not eligible exposure. [pmid: 15088924].
1055 Choe JM. Surgical implantation of the synthetic sling (the 6-point fixation technique and weight-adjusted spacing nomogram): technique and results. Adv Exp Med Biol. 2003;539:493-507. Not eligible exposure. [pmid: 15088925].
1056 Choe JM, Ogan K, Battino BS. Antimicrobial mesh versus vaginal wall sling: a comparative outcomes analysis. J Urol. Jun. 2000;163(6):1829-34. Not eligible exposure. [pmid: 10799192].
1057 Choe JM, Ogan K, Bennett S. Antibacterial mesh sling: a prospective outcome analysis. Urology. Apr. 2000;55(4):515-20. Not eligible exposure. [pmid: 10736494].
1058 Cholhan HJ, Lotze PM. Voiding function after a modified no-tension pubovaginal sling. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2004;15(4):249-56. Not eligible exposure. [pmid: 15517669].
1059 Choo MS, Ku JH, Lee JB, et al. Cross-cultural differences for adapting overactive bladder symptoms: results of an epidemiologic survey in Korea. World J Urol. Oct. 2007;25(5):505-11. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17569056].
1060 Choo MS, Ku JH, Oh SJ, et al. Prevalence of urinary incontinence in Korean women:an epidemiologic survey. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2007;18(11):1309-15. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17912572].
1061 Chopra B, Barrick SR, Meyers S, et al. Expression and function of bradykinin B1 and B2 receptors in normal and inflamed rat urinary bladder urothelium. J Physiol. Feb. 1. 2005;562(Pt 3):859-71. Not eligible target population. [pmid: 15576455].
1062 Christensen H, Laybourn C, Eickhoff JH, et al. Long-term results of the Stamey Bladder-neck suspension procedure and of the Burch colposuspension. Scand J Urol Nephrol. Aug. 1997;31(4):349-53. Not eligible exposure. [pmid: 9290164].
1063 Christie D, Denham J, Steigler A, et al. Delayed rectal and urinary symptomatology in patients treated for prostate cancer by radiotherapy with or without short term neo-adjuvant androgen deprivation. Radiother Oncol. Nov. 2005;77(2):117-25. Not eligible target population. [pmid: 16271786].
1064 Chrouser KL, Fick F, Goel A, et al. Carbon coated zirconium beads in beta-glucan gel and bovine glutaraldehyde cross-linked collagen injections for intrinsic sphincter deficiency: continence and satisfaction after extended followup. J Urol. Mar. 2004;171(3):1152-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14767290].
1065 Chu FM, Dmochowski R. Pathophysiology of overactive bladder. Am J Med. Mar. 2006;119(3 Suppl 1):3-8. Review. [pmid: 16483862].
1066 Chuang YC, Fraser MO, Yu Y, et al. The role of bladder afferent pathways in bladder hyperactivity induced by the intravesical administration of nerve growth factor. J Urol. Mar. 2001;165(3):975-9. Not eligible target population. [pmid: 11176525].
1067 Chun FK, Walz J, Gallina A, et al. Stress Urinary Incontinence and Erectile Dsyfunction in a Prostate Cancer Screening Cohort. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Not eligible target population.
1068 Cimentepe E, Unsal A, Saglam R. Randomized clinical trial comparing transurethral needle ablation with transurethral resection of the prostate for the treatment of benign prostatic hyperplasia: results at 18 months. J Endourol. Mar. 2003;17(2):103-7. Not eligible target population. [pmid: 12689404].
1069 Cindolo L, Salzano L, Rota G, et al. Tension-free transobturator approach for female stress urinary incontinence. Minerva Urol Nefrol. Mar. 2004;56(1):89-98. Not eligible exposure. [pmid: 15195034].
1070 Citterio A, Franceschini M, Spizzichino L, et al. Nontraumatic spinal cord injury: an Italian survey. Arch Phys Med Rehabil. Sep. 2004;85(9):1483-7. Not eligible target population. [pmid: 15375821].
1071 Clancy B, Malone-Lee J. Reducing the leakage of body-worn incontinence pads. J Adv Nurs. Feb. 1991;16(2):187-93. Not eligible target population. [pmid: 2013661].
1072 Clark AL, Gregory T, Smith VJ, et al. Epidemiologic evaluation of reoperation for surgically treated pelvic organ prolapse and urinary incontinence. Am J Obstet Gynecol. Nov. 2003;189(5):1261-7. Not eligible exposure. [pmid: 14634551].
1073 Clark JA, Bokhour BG, Inui TS, et al. Measuring patients’ perceptions of the outcomes of treatment for early prostate cancer. Med Care. Aug. 2003;41(8):923-36. Not eligible target population. [pmid: 12886172].
1074 Clark JA, Talcott JA. Symptom indexes to assess outcomes of treatment for early prostate cancer. Med Care. Oct. 2001;39(10):1118-30. Not eligible target population. [pmid: 11567174].
1075 Clarke-O’Neill S, Pettersson L, Fader M. An evaluation of disposable pads for women with light incontinence. Nurs Times. May. 13–19. 2003;99(19):69-72. Not eligible outcomes. [pmid: 12768980].
1076 Clayman C, Thompson V, Forth H. Development of a continence assessment pathway in acute care. Nursing times. May. 3–9. 2005;101(18):46-8. Not eligible target population. [pmid: 15892505].
1077 Clayton J, Smith K, Qureshi H, et al. Collecting patients’ views and perceptions of continence services: the development of research instruments. J Adv Nurs. Aug. 1998;28(2):353-61. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9725733].
1078 Clemens JQ, Markossian TW, Meenan RT, et al. Overlap of voiding symptoms, storage symptoms and pain in men and women. J Urol. Oct. 2007;178(4 Pt 1):1354-8. discussion 8. Not eligible exposure. [pmid: 17706719].
1079 Clyne OJ, O’Sullivan O, Flood HD. Pubovaginal sling for urodynamic stress incontinence: effect on patient quality of life. Ir Med J. Mar. 2005;98(3):75-7. Not eligible exposure. [pmid: 15869063].
1080 Cochran A. Response to urinary incontinence by older persons living in the community. J Wound Ostomy Continence Nurs. Nov. 1998;25(6):296-303. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9919145].
1081 Cochran A. Don’t ask, don’t tell: the incontinence conspiracy. Manag Care Q. Winter. 2000;8(1):44-52. Not eligible exposure. [pmid: 11009733].
1082 Coffey A, McCarthy G, McCormack B, et al. Incontinence: assessment, diagnosis, and management in two rehabilitation units for older people. Worldviews Evid Based Nurs. 2007;4(4):179-86. Not eligible target population. [pmid: 18076461].
1083 Cohen SJ, Robinson D, Dugan E, et al. Communication between older adults and their physicians about urinary incontinence. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. Jan. 1999;54(1):M34-7. Not eligible target population. [pmid: 21160].
1084 Cohn JH, El-Galley R. Radical prostatectomy in a community practice. J Urol. Jan. 2002;167(1):224-8. Not eligible target population. [pmid: 11743311].
1085 Collette C, Leclerc G, Tu le M. Effectiveness of a geriatric urinary incontinence educational program for nursing staff. Nurs Leadersh (Tor Ont). 2003;16(4):99-109. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14983927].
1086 Colley W. Continence. Indwelling urinary catheters. Nurs Times. Oct 26–Nov 1. 1994;90(43):70. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7984468].
1087 Colling J, Owen TR, McCreedy M, et al. The effects of a continence program on frail community-dwelling elderly persons. Urol Nurs. Apr. 2003;23(2):117-22. 27. 31. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12778826].
1088 Coll-Planas L, Denkinger MD, Nikolaus T. Relationship of urinary incontinence and late-life disability: implications for clinical work and research in geriatrics. Z Gerontol Geriatr. Aug. 2008;41(4):283-90. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18685805].
1089 Collste L. Phenylpropanolamine in treatment of female stress urinary incontinence. Urology. October. 1987. 1987;30(4). Not eligible exposure. [pmid: 3310369].
1090 Colombo M, Maggioni A, Scalambrino S, et al. Surgery for genitourinary prolapse and stress incontinence: a randomized trial of posterior pubourethral ligament plication and Pereyra suspension. Am J Obstet Gynecol. Feb. 1997;176(2):337-43. Not eligible exposure. [pmid: 9065178].
1091 Colombo M, Maggioni A, Zanetta G, et al. Prevention of postoperative urinary stress incontinence after surgery for genitourinary prolapse. Obstet Gynecol. Feb. 1996;87(2):266-71. Not eligible exposure. [pmid: 8559537].
1092 Colombo M, Milani R, Vitobello D, et al. A randomized comparison of Burch colposuspension and abdominal paravaginal defect repair for female stress urinary incontinence. Am J Obstet Gynecol. Jul. 1996;175(1):78-84. Not eligible exposure. [pmid: 8694079].
1093 Colombo M, Scalambrino S, Maggioni A, et al. Burch colposuspension versus modified Marshall-Marchetti-Krantz urethropexy for primary genuine stress urinary incontinence: a prospective, randomized clinical trial. Am J Obstet Gynecol. Dec. 1994;171(6):1573-9. Not eligible exposure. [pmid: 7802070].
1094 Colombo M, Vitobello D, Proietti F, et al. Randomised comparison of Burch colposuspension versus anterior colporrhaphy in women with stress urinary incontinence and anterior vaginal wall prolapse. BJOG. Apr. 2000;107(4):544-51. Not eligible exposure. [pmid: 10759276].
1095 Colombo T, Augustin H, Breinl E, et al. The use of polydimethylsiloxane in the treatment of incontinence after radical prostatectomy. Br J Urol. Dec. 1997;80(6):923-6. Not eligible target population. [pmid: 9439411].
1096 Comiter CV, Colegrove PM. High rate of vaginal extrusion of silicone-coated polyester sling. Urology. Jun. 2004;63(6):1066-70. Not eligible exposure. [pmid: 15183951].
1097 Connor JP, Betrus G, Fleming P, et al. Early cystometrograms can predict the response to intravesical instillation of oxybutynin chloride in myelomeningocele patients. J Urol. Apr. 1994;151(4):1045-7. Not eligible target population. [pmid: 8126787].
1098 Connor PA, Kooker BM. Nurses’ knowledge, attitudes, and practices in managing urinary incontinence in the acute care setting. Medsurg Nurs. Apr. 1996;5(2):87-92. 117. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8704792].
1099 Conrad S, Pieper A, De la Maza SF, et al. Long-term results of the Stamey bladder neck suspension procedure: a patient questionnaire based outcome analysis. J Urol. May. 1997;157(5):1672-7. Not eligible exposure. [pmid: 9112503].
1100 Constantinou CE. Pharmacologic treatment of detrusor incontinence with thiphenamil HCl. Urol Int. 1992;48(1):42-7. Not eligible exposure. [pmid: 1598734].
1101 Coombes GM, Millard RJ. Urinary urge incontinence: randomised crossover trials of penthienate versus placebo and propantheline. Med J Aust. Nov. 4. 1996;165(9):473-6. Not eligible exposure. [pmid: 8937366].
1102 Cooper G, Watt E. An exploration of acute care nurses’ approach to assessment and management of people with urinary incontinence. J Wound Ostomy Continence Nurs. Nov. 2003;30(6):305-13. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14615759].
1103 Cooper P, Gray D. Comparison of two skin care regimes for incontinence. Br J Nurs. Mar. 2001;10(6 Suppl):S6. S8. S10 passim. Not eligible target population. [pmid: 12070396].
1104 Cooperberg MR, Master VA, Carroll PR. Health related quality of life significance of single pad urinary incontinence following radical prostatectomy. J Urol. Aug. 2003;170(2 Pt 1):512-5. Not eligible target population. [pmid: 12853811].
1105 Copas P, Bukovsky A, Asbury B, et al. Estrogen, progesterone, and androgen receptor expression in levator ani muscle and fascia. J Womens Health Gend Based Med. Oct. 2001;10(8):785-95. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11703891].
1106 Corcos J, Behlouli H, Beaulieu S. Identifying cut-off scores with neural networks for interpretation of the incontinence impact questionnaire. Neurourol Urodyn. 2002;21(3):198-203. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11948712].
1107 Corcos J, Gajewski J, Heritz D, et al. Canadian Urological Association guidelines on urinary incontinence. Canadian Journal of Urology. Jun. 2006;13(3):3127-38. Guideline. [pmid: 16813704].
1108 Cortesse A, Jacquetin B, Grise P, et al. Prospective multicenter clinical trial of Uretex Sup for surgical treatment of stress urinary incontinence. Int J Urol. Jul. 2007;14(7):611-5. Not eligible exposure. [pmid: 17645604].
1109 Costantini E, Lazzeri M, Bini V, et al. Burch colposuspension does not provide any additional benefit to pelvic organ prolapse repair in patients with urinary incontinence: a randomized surgical trial. J Urol. Sep. 2008;180(3):1007-12. Not eligible exposure. [pmid: 18639302].
1110 Costantini E, Lazzeri M, Giannantoni A, et al. Preoperative Valsalva leak point pressure may not predict outcome of mid-urethral slings. Analysis from a randomized controlled trial of retropubic versus transobturator mid-urethral slings. Int Braz J Urol. Jan–Feb. 2008;34(1):73-81. discussion -3. Not eligible exposure. [pmid: 18341724].
1111 Costantini E, Mearini L, Biscotto S, et al. Impact of different sized catheters on pressure-flow studies in women with lower urinary tract symptoms. Neurourol Urodyn. 2005;24(2):106-10. Not eligible exposure. [pmid: 15616966].
1112 Costantini E, Mearini L, Mearini E, et al. Assessing outcome after a modified vaginal wall sling for stress incontinence with intrinsic sphincter deficiency. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2005;16(2):138-46. discussion 46. Not eligible exposure. [pmid: 15789147].
1113 Costantini E, Zucchi A, Giannantoni A, et al. Must colposuspension be associated with sacropexy to prevent postoperative urinary incontinence?. Eur Urol. Mar. 2007;51(3):788-94. Not eligible exposure. [pmid: 17011699].
1114 Coucke K, Kesteloot K. A comparison of health care financing policies for incontinence products in European countries. Eur Urol. Jan. 2000;37(1):36-42. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10671783].
1115 Couillard DR, Deckard-Janatpour KA, Stone AR. The vaginal wall sling: a compressive suspension procedure for recurrent incontinence in elderly patients. Urology. Feb. 1994;43(2):203-8. Not eligible exposure. [pmid: 8116116].
1116 Coyne KS, Margolis MK, Brewster-Jordan J, et al. Evaluating the impact of overactive bladder on sexual health in women: what is relevant?. J Sex Med. Jan. 2007;4(1):124-36. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17034411].
1117 Coyne KS, Matza LS, Thompson C, et al. The responsiveness of the OAB-q among OAB patient subgroups. Neurourol Urodyn. 2007;26(2):196-203. Not eligible outcomes. [pmid: 17016794].
1118 Coyne KS, Matza LS, Thompson CL. The responsiveness of the Overactive Bladder Questionnaire (OAB-q). Qual Life Res. Apr. 2005;14(3):849-55. Not eligible outcomes. [pmid: 16022077].
1119 Coyne KS, Payne C, Bhattacharyya SK, et al. The impact of urinary urgency and frequency on health-related quality of life in overactive bladder: results from a national community survey. Value Health. Jul–Aug. 2004;7(4):455-63. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15449637].
1120 Coyne KS, Sexton CC, Irwin DE, et al. The impact of overactive bladder, incontinence and other lower urinary tract symptoms on quality of life, work productivity, sexuality and emotional well-being in men and women: results from the EPIC study. BJU Int. Jun. 2008;101(11):1388-95. Not eligible exposure. [pmid: 18454794].
1121 Coyne KS, Wein AJ, Tubaro A, et al. The burden of lower urinary tract symptoms: evaluating the effect of LUTS on health-related quality of life, anxiety and depression: EpiLUTS. BJU Int. Apr. 2009;103(Suppl 3):4-11. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 19302497].
1122 Coyne KS, Zhou Z, Thompson C, et al. The impact on health-related quality of life of stress, urge and mixed urinary incontinence. BJU Int. Nov. 2003;92(7):731-5. Not eligible exposure. [pmid: 14616456].
1123 Craig JB, Noblett KL, Conner CA, et al. Reconstructive pelvic surgery and plastic surgery: safety and efficacy of combined surgery. Am J Obstet Gynecol. Dec. 2008;199(6):701 e1-5. Not eligible exposure. [pmid: 18845294].
1124 Cramer EH, Jones P, Keenan NL, et al. Is naturopathy as effective as conventional therapy for treatment of menopausal symptoms?. J Altern Complement Med. Aug. 2003;9(4):529-38. Not eligible target population. [pmid: 14499029].
1125 Creasey GH, Kilgore KL, Brown-Triolo DL, et al. Reduction of costs of disability using neuroprostheses. Assist Technol. 2000;12(1):67-75. Not eligible target population. [pmid: 11067579].
1126 Crimmins CR, Rathbun SR, Husmann DA. Management of urinary incontinence and nocturnal enuresis in attention-deficit hyperactivity disorder. J Urol. Oct. 2003;170(4 Pt 1):1347-50. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14501767].
1127 Crivellaro S, Smith JJ, Kocjancic E, et al. Transvaginal sling using acellular human dermal allograft: safety and efficacy in 253 patients. J Urol. Oct. 2004;172(4 Pt 1):1374-8. Not eligible exposure. [pmid: 15371848].
1128 Crosbie JJ, Eguare E, McGovern B, et al. The influence of bladder filling on anorectal function. Colorectal Dis. May. 2003;5(3):251-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12780887].
1129 Cucchi A, Quaglini S, Rovereto B. Relationships between micturition urgency and involuntary voiding dynamics in men with urinary incontinence from idiopathic detrusor overactivity. J Urol. Aug. 2007;178(2):563-7. discussion 7. Not eligible target population. [pmid: 17570436].
1130 Cullen B. There’s no place like home. J Wound Ostomy Continence Nurs. Nov. 1997;24(6):289-90. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9407821].
1131 Cullen B. Roles for the WOC nurse in a disaster. J Wound Ostomy Continence Nurs. May–Jun. 2008;35(3):282-6. Not eligible target population. [pmid: 18496084].
1132 Culligan PJ, Goldberg RP, Blackhurst DW, et al. Comparison of microtransducer and fiberoptic catheters for urodynamic studies. Obstet Gynecol. Aug. 2001;98(2):253-7. Not eligible exposure. [pmid: 11506841].
1133 Culligan PJ, Goldberg RP, Sand PK. A randomized controlled trial comparing a modified Burch procedure and a suburethral sling: long-term follow-up. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2003;14(4):229-33. discussion 33. Not eligible exposure. [pmid: 14530832].
1134 Culligan PJ, Myers JA, Goldberg RP, et al. Elective cesarean section to prevent anal incontinence and brachial plexus injuries associated with macrosomia--a decision analysis. Int Urogynecol J Pelvic Floor Dysfunct. Jan–Feb. 2005;16(1):19-28. discussion 15647962. Not eligible target population. [pmid: 15647962].
1135 Cummings V, Holt R, van der Sloot C, et al. Costs and management of urinary incontinence in long-term care. J Wound Ostomy Continence Nurs. Jul. 1995;22(4):193-8. Not eligible target population. [pmid: 7627295].
1136 Cundiff GW, Varner E, Visco AG, et al. Risk factors for mesh/suture erosion following sacral colpopexy. Am J Obstet Gynecol. Dec. 2008;199(6):688 e1-5. Not eligible exposure. [pmid: 18976976].
1137 Cunningham RS. Clinical practice guideline use by oncology advanced practice nurses. Applied Nursing Research. Aug. 2006;19(3):126-33. Not eligible target population. [pmid: 16877191].
1138 Currie CJ, McEwan P, Poole CD, et al. The impact of the overactive bladder on health-related utility and quality of life. BJU Int. Jun. 2006;97(6):1267-72. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16686724].
1139 Curtis MR, Gormley EA, Latini JM, et al. Prospective development of a cost-efficient program for the pubovaginal sling. Urology. Jan. 1997;49(1):41-5. Not eligible exposure. [pmid: 9000183].
1140 Cusick G, Birkett A, Clarke-O’Neill S, et al. A system for logging incontinence events using a simple disposable sensor. Proc Inst Mech Eng [H]. 2003;217(4):305-10. Not eligible target population. [pmid: 12885201].
1141 Dahlen HG, Homer CS, Cooke M, et al. Perineal outcomes and maternal comfort related to the application of perineal warm packs in the second stage of labor: a randomized controlled trial. Birth. Dec. 2007;34(4):282-90. Not eligible target population. [pmid: 18021143].
1142 Dainer M, Hall CD, Choe J, et al. Pregnancy following incontinence surgery. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(6):385-90. Not eligible exposure. [pmid: 9891960].
1143 Dainer MJ, Zorn BH. Burch-Cooper’s ligament sling procedure: an augmented incontinence operation. Tech Urol. Sep. 2000;6(3):175-7. Not eligible exposure. [pmid: 10963481].
1144 Dalkin BL, Christopher BA, Shawler D. Health related quality of life outcomes after radical prostatectomy: attention to study design and the patient-based importance of single-surgeon studies. Urol Oncol. Jan–Feb. 2006;24(1):28-32. Not eligible target population. [pmid: 16414489].
1145 Dalkin BL, Wessells H, Cui H. A national survey of urinary and health related quality of life outcomes in men with an artificial urinary sphincter for post-radical prostatectomy incontinence. J Urol. Jan. 2003;169(1):237-9. Not eligible target population. [pmid: 12478144].
1146 Damen-Elias HA, Luijnenburg SE, Visser GH, et al. Mild pyelectasis diagnosed by prenatal ultrasound is not a predictor of urinary tract morbidity in childhood. Prenat Diagn. Dec. 2005;25(13):1239-47. Not eligible target population. [pmid: 16353272].
1147 Damon H, Schott AM, Barth X, et al. Clinical characteristics and quality of life in a cohort of 621 patients with faecal incontinence. Int J Colorectal Dis. Sep. 2008;23(9):845-51. Not eligible target population. [pmid: 18506453].
1148 Daneshgari F, Moore C, Frinjari H, et al. Patient related risk factors for recurrent stress urinary incontinence surgery in women treated at a tertiary care center. J Urol. Oct. 2006;176(4 Pt 1):1493-9. Not eligible exposure. [pmid: 16952667].
1149 Daneshgari F, Sorensen C. Practice pattern of urologists in the Rocky Mountains region with regard to use of urodynamic studies. Urology. May. 2003;61(5):942-5. Not eligible exposure. [pmid: 12736012].
1150 Darai E, Coutant C, Rouzier R, et al. Genital prolapse repair using porcine skin implant and bilateral sacrospinous fixation: midterm functional outcome and quality-of-life assessment. Urology. Feb. 2009;73(2):245-50. Not eligible exposure. [pmid: 19038431].
1151 Darai E, Frobert JL, Grisard-Anaf M, et al. Functional results after the suburethral sling procedure for urinary stress incontinence: a prospective randomized multicentre study comparing the retropubic and transobturator routes. Eur Urol. Mar. 2007;51(3):795-801. discussion -2. Not eligible exposure. [pmid: 17010507].
1152 Darkow T, Fontes CL, Williamson TE. Costs associated with the management of overactive bladder and related comorbidities. Pharmacotherapy. Apr. 2005;25(4):511-9. Not eligible outcomes. [pmid: 15977912].
1153 Das AK, Carlson AM, Hull M. Improvement in depression and health-related quality of life after sacral nerve stimulation therapy for treatment of voiding dysfunction. Urology. Jul. 2004;64(1):62-8. Not eligible target population. [pmid: 15245937].
1154 Das P, Smith JJ, Tekkis PP, et al. Quality of life after indefinite diversion/pouch excision in ileal pouch failure patients. Colorectal Dis. Oct. 2007;9(8):718-24. Not eligible target population. [pmid: 17764535].
1155 Das S. Comparative outcome analysis of laparoscopic colposuspension, abdominal colposuspension and vaginal needle suspension for female urinary incontinence. J Urol. Aug. 1998;160(2):368-71. Not eligible exposure. [pmid: 9679879].
1156 Dattilo J. A long-term study of patient outcomes with pelvic muscle re-education for urinary incontinence. J Wound Ostomy Continence Nurs. Jul. 2001;28(4):199-205. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11452256].
1157 Dave S, Grover VP, Agarwala S, et al. The role of imipramine therapy in bladder exstrophy after bladder neck reconstruction. BJU Int. Apr. 2002;89(6):557-60. discussion 60–1. Not eligible target population. [pmid: 11942963].
1158 David A. Another one bites the dust. Nurs Times. May. 18–24. 2000;96(20):23. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11989445].
1159 David-Montefiore E, Frobert JL, Grisard-Anaf M, et al. Peri-operative complications and pain after the suburethral sling procedure for urinary stress incontinence: a French prospective randomised multicentre study comparing the retropubic and transobturator routes. Eur Urol. Jan. 2006;49(1):133-8. Not eligible exposure. [pmid: 16310932].
1160 Davila GW. Advances in anticholinergic therapy delivery systems. Geriatrics. May. 2002;57(Suppl 1):29-34. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12040601].
1161 Davila GW, Ghoniem GM, Kapoor DS, et al. Pelvic floor dysfunction management practice patterns: a survey of members of the International Urogynecological Association. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(5):319-25. Not eligible exposure. [pmid: 12355293].
1162 Davila GW, Neal D, Horbach N, et al. A bladder-neck support prosthesis for women with stress and mixed incontinence. Obstet Gynecol. Jun. 1999;93(6):938-42. Not eligible exposure. [pmid: 10362158].
1163 Davila GW, Stanford E, Korn A. Prospective trial of gasless laparoscopic Burch colposuspension using conventional surgical instruments. J Am Assoc Gynecol Laparosc. May. 2004;11(2):197-203. Not eligible exposure. [pmid: 15200775].
1164 Davila GW, Starkman JS, Dmochowski RR. Transdermal oxybutynin for overactive bladder. Urol Clin North Am. Nov. 2006;33(4):455-63. viii. Review. [pmid: 17011381].
1165 Davila HH, Weber T, Burday D, et al. Total or partial prostate sparing cystectomy for invasive bladder cancer: long-term implications on erectile function. BJU Int. Nov. 2007;100(5):1026-9. Not eligible target population. [pmid: 17868423].
1166 Davis C. The cost of containment. Nurs Older People. Apr. 2008;20(3):24-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18500130].
1167 Davis TL, Lukacz ES, Luber KM, et al. Determinants of patient satisfaction after the tension-free vaginal tape procedure. Am J Obstet Gynecol. Jul. 2004;191(1):176-81. Not eligible exposure. [pmid: 15295361].
1168 Davison BJ, Goldenberg SL. Decisional regret and quality of life after participating in medical decision-making for early-stage prostate cancer. BJU Int. Jan. 2003;91(1):14-7. Not eligible target population. [pmid: 12614242].
1169 Day K. Urinary continence promotion: a role for all nurses. Collegian. Oct. 2000;7(4):40-2. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11858311].
1170 Day PL. Findings of a three-year retrospective study to investigate prevalence and incidence of urinary incontinence and overactive bladder in a typical managed care setting. Pharm Pract Manag Q. Apr. 2000;20(1):1-11. Not eligible target population. [pmid: 10947537].
1171 de Aloysio D, Altieri P, Penacchioni P, et al. Premenopause-dependent changes. Gynecol Obstet Invest. 1996;42(2):120-7. Not eligible target population. [pmid: 8878718].
1172 de Araujo MP, Faria AC, Takano CC, et al. Urodynamic study and quality of life in patients with fibromyalgia and lower urinary tract symptoms. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2008;19(8):1103-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18317663].
1173 De Deyn PP, Carrasco MM, Deberdt W, et al. Olanzapine versus placebo in the treatment of psychosis with or without associated behavioral disturbances in patients with Alzheimer’s disease. Int J Geriatr Psychiatry. Feb. 2004;19(2):115-26. Not eligible target population. [pmid: 14758577].
1174 De E, Pisters LL, Pettaway CA, et al. Salvage prostatectomy with bladder neck closure, continent catheterizable stoma and bladder augmentation: feasibility and patient reported continence outcomes at 32 months. J Urol. Jun. 2007;177(6):2200-4. discussion 4. Not eligible target population. [pmid: 17509319].
1175 De Gennaro M, Capitanucci ML, Mastracci P, et al. Percutaneous tibial nerve neuromodulation is well tolerated in children and effective for treating refractory vesical dysfunction. J Urol. May. 2004;171(5):1911-3. Not eligible target population. [pmid: 15076308].
1176 de Kort LM, Klijn AJ, Dik P, et al. Oxybutynin for diagnosis of infravesical obstruction in boys with urinary incontinence. Urology. Jul. 2003;62(1):127-30. discussion 30–1. Not eligible target population. [pmid: 12837438].
1177 de la Portilla F, Rada R, Vega J, et al. Evaluation of the use of posterior tibial nerve stimulation for the treatment of fecal incontinence: preliminary results of a prospective study. Dis Colon Rectum. Aug. 2009;52(8):1427-33. Not eligible target population. [pmid: 19617756].
1178 de Leval J, Waltregny D. The inside-out trans-obturator sling: a novel surgical technique for the treatment of male urinary incontinence. Eur Urol. Nov. 2008;54(5):1051-65. Not eligible target population. [pmid: 18036729].
1179 de Reijke TM, de Boer EC, Kurth KH, et al. Urinary cytokines during intravesical bacillus Calmette-Guerin therapy for superficial bladder cancer: processing, stability and prognostic value. J Urol. Feb. 1996;155(2):477-82. Not eligible target population. [pmid: 8558640].
1180 de Seze M, Gallien P, Denys P, et al. Intravesical glucidic capsaicin versus glucidic solvent in neurogenic detrusor overactivity: a double blind controlled randomized study. Neurourol Urodyn. 2006;25(7):752-7. Not eligible exposure. [pmid: 16986136].
1181 de Sèze M, Wiart L, Joseph PA, et al. Capsaicin and neurogenic detrusor hyperreflexia: a double-blind placebo-controlled study in 20 patients with spinal cord lesions. Neurourology and urodynamics. 1998;(5):513-23. Not eligible target population. [pmid: 9776014].
1182 de Tayrac R, Deffieux X, Resten A, et al. A transvaginal ultrasound study comparing transobturator tape and tension-free vaginal tape after surgical treatment of female stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2006;17(5):466-71. Not eligible exposure. [pmid: 16311712].
1183 Debodinance P, Delporte P, Engrand JB, et al. Tension-free vaginal tape (TVT) in the treatment of urinary stress incontinence: 3 years experience involving 256 operations. Eur J Obstet Gynecol Reprod Biol. Oct. 10. 2002;105(1):49-58. Not eligible exposure. [pmid: 12270565].
1184 Debodinance P, Querleu D. Comparison of the Bologna and Ingelman-Sundberg procedures for stress incontinence associated with genital prolapse: prospective randomized study. Eur J Obstet Gynecol Reprod Biol. Nov. 1993;52(1):35-40. Not eligible exposure. [pmid: 8119472].
1185 Deffieux X, Donnadieu AC, Porcher R, et al. Long-term results of tension-free vaginal tape for female urinary incontinence: follow up over 6 years. Int J Urol. Jun. 2007;14(6):521-6. Not eligible exposure. [pmid: 17593097].
1186 Defreitas GA, Wilson TS, Zimmern PE, et al. Three-dimensional ultrasonography: an objective outcome tool to assess collagen distribution in women with stress urinary incontinence. Urology. Aug. 2003;62(2):232-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12893325].
1187 Dehkharghani S, Bible J, Chen JG, et al. The economic burden of skin disease in the United States. J Am Acad Dermatol. Apr. 2003;48(4):592-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12664024].
1188 Del Popolo G, Filocamo MT, Li Marzi V, et al. Neurogenic detrusor overactivity treated with english botulinum toxin a: 8-year experience of one single centre. Eur Urol. May. 2008;53(5):1013-19. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17950989].
1189 Del Priore G, Taylor SY, Esdaile BA, et al. Urinary incontinence in gynecological oncology patients. Int J Gynecol Cancer. Sep–Oct. 2005;15(5):911-4. Not eligible target population. [pmid: 16174244].
1190 Delancey JO, Kane Low L, Miller JM, et al. Graphic integration of causal factors of pelvic floor disorders: an integrated life span model. Am J Obstet Gynecol. Dec. 2008;199(6):610 e1-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18533115].
1191 DeLancey JO, Sampselle CM, Punch MR. Kegel dyspareunia: levator ani myalgia caused by overexertion. Obstet Gynecol. Oct. 1993;82(4 Pt 2 Suppl):658-9. Not eligible target population. [pmid: 8378003].
1192 Deliveliotis C, Delis A, Papatsoris A, et al. Local steroid application during nerve-sparing radical retropubic prostatectomy. BJU Int. Sep. 2005;96(4):533-5. Not eligible target population. [pmid: 16104905].
1193 Deliveliotis C, Liakouras C, Delis A, et al. Prostate operations: long-term effects on sexual and urinary function and quality of life. Comparison with an age-matched control population. Urol Res. Aug. 2004;32(4):283-9. Not eligible target population. [pmid: 15057494].
1194 Delo DM, Eberli D, Williams JK, et al. Angiogenic gene modification of skeletal muscle cells to compensate for ageing-induced decline in bioengineered functional muscle tissue. BJU Int. Sep. 2008;102(7):878-84. Not eligible target population. [pmid: 18489526].
1195 Demirci F, Ozdemir I, Somunkiran A, et al. Abdominal sacrohysteropexy in young women with uterovaginal prolapse: results of 20 cases. J Reprod Med. Jul. 2006;51(7):539-43. Not eligible exposure. [pmid: 16913544].
1196 Demirkesen O, Onal B, Tunc B, et al. Assessment of the continence status and patients’ satisfaction after retropubic radical prostatectomy: a questionnaire based study. Int Urol Nephrol. 2007;39(2):531-6. Not eligible target population. [pmid: 17006734].
1197 Denberg TD, Flanigan RC, Kim FJ, et al. Self-reported volume of radical prostatectomies among urologists in the USA. BJU Int. Feb. 2007;99(2):339-43. Not eligible target population. [pmid: 17155974].
1198 Denman MA, Gregory WT, Boyles SH, et al. Reoperation 10 years after surgically managed pelvic organ prolapse and urinary incontinence. Am J Obstet Gynecol. May. 2008;198(5):555 e1-5. Not eligible exposure. [pmid: 18355779].
1199 Denton S. Let’s bring continence out into the open. Nurs Times. Jul 26-Aug 1. 2001;97(30):51. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11957957].
1200 Derikx JP, De Backer A, van de Schoot L, et al. Long-term functional sequelae of sacrococcygeal teratoma: a national study in The Netherlands. J Pediatr Surg. Jun. 2007;42(6):1122-6. Not eligible target population. [pmid: 17560233].
1201 Desai MM, Zhang P, Hennessy CH. Surveillance for morbidity and mortality among older adults--United States, 1995–1996. MMWR CDC Surveill Summ. Dec. 17. 1999;48(8):7-25. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10634269].
1202 Desai N, Keane T, Wagg A, et al. Provision of continence pads by the continence services in Great Britain: fair all round?. J Wound Ostomy Continence Nurs. Sep–Oct. 2008;35(5):510-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18794703].
1203 deTayrac R, Deffieux X, Droupy S, et al. A prospective randomized trial comparing tension-free vaginal tape and transobturator suburethral tape for surgical treatment of stress urinary incontinence. Am J Obstet Gynecol. Mar. 2004;190(3):602-8. Not eligible exposure. [pmid: 15041987].
1204 Deval B, Ferchaux J, Berry R, et al. Objective and subjective cure rates after trans-obturator tape (OBTAPE) treatment of female urinary incontinence. Eur Urol. Feb. 2006;49(2):373-7. Not eligible exposure. [pmid: 16413657].
1205 Deval B, Jeffry L, Al Najjar F, et al. Determinants of patient dissatisfaction after a tension-free vaginal tape procedure for urinary incontinence. J Urol. May. 2002;167(5):2093-7. Not eligible exposure. [pmid: 11956447].
1206 Di Carlo A, Lamassa M, Pracucci G, et al. Stroke in the very old: clinical presentation and determinants of 3-month functional outcome: A European perspective. European BIOMED Study of Stroke Care Group. Stroke. Nov. 1999;30(11):2313-9. no associative hypothesis tested. [pmid: 10548664].
1207 Di Gangi Herms AM, Pinggera GM, De Jonge P, et al. Assessing health care needs and clinical outcome with urological case complexity: a study using INTERMED. Psychosomatics. May–Jun. 2003;44(3):196-203. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12724500].
1208 Diamond DA, Quimby GF, Rink RC, et al. Use of the silastic sheath in bladder neck reconstruction. The Scientific World Journal. 2004:103-7. not eligible exposure.
1209 Dickersin K, Munro M, Langenberg P, et al. Surgical Treatments Outcomes Project for Dysfunctional Uterine Bleeding (STOP-DUB): design and methods. Control Clin Trials. Oct. 2003;24(5):591-609. Not eligible target population. [pmid: 14500057].
1210 Dierich M. A retrospective review of outcomes in one clinic’s treatment of urinary incontinence. Urol Nurs. Dec. 1998;18(4):283-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9873354].
1211 Dietz HP, Barry C, Lim YN, et al. Two-dimensional and three-dimensional ultrasound imaging of suburethral slings. Ultrasound Obstet Gynecol. Aug. 2005;26(2):175-9. Not eligible exposure. [pmid: 15988786].
1212 Dietz HP, Foote AJ, Mak HL, et al. TVT and Sparc suburethral slings: a case-control series. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2004;15(2):129-31. discussion 31. Not eligible exposure. [pmid: 15014941].
1213 Dietz HP, Jarvis SK, Vancaillie TG. The assessment of levator muscle strength: a validation of three ultrasound techniques. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(3):156-9. discussion 9. Not eligible outcomes. [pmid: 12140708].
1214 Dietz V, de Jong J, Huisman M, et al. The effectiveness of the sacrospinous hysteropexy for the primary treatment of uterovaginal prolapse. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2007;18(11):1271-6. Not eligible exposure. [pmid: 17384894].
1215 Dietz V, Huisman M, de Jong JM, et al. Functional outcome after sacrospinous hysteropexy for uterine descensus. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2008;19(6):747-52. Not eligible target population. [pmid: 18297228].
1216 Digesu G, Hewett S, Hendricken C, et al. Does the onset or bother of mixed urinary incontinence help in the urodynamic diagnosis?. Paper presented at: Neurourology and Urodynamics, 2010; Joint Meeting of the International Continence Society and the International Urogynecological Association. Toronto, Canada. 23–27 August 2010. Not eligible exposure.
1217 Digesu GA, Chaliha C, Salvatore S, et al. The relationship of vaginal prolapse severity to symptoms and quality of life. BJOG. Jul. 2005;112(7):971-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15958002].
1218 Digesu GA, Khullar V, Panayi D, et al. Should we explain lower urinary tract symptoms to patients? Neurourology &. Urodynamics. 2008;27(5):368-71. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 21147].
1219 Digesu GA, Robinson D, Cardozo L, et al. Three-dimensional ultrasound of the urethral sphincter predicts continence surgery outcome. Neurourology & Urodynamics. 2009;28(1):90-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18726938].
1220 Digesu GA, Salvatore S, Fernando R, et al. Mixed urinary symptoms: what are the urodynamic findings? Neurourology &. Urodynamics. 2008;27(5):372-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 21146].
1221 Dinc A, Kizilkaya Beji N, Yalcin O. Effect of pelvic floor muscle exercises in the treatment of urinary incontinence during pregnancy and the postpartum period. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2009;20(10):1223-31. Not eligible target population. [pmid: 19649552].
1222 Dingwall L. Promoting social continence using incontinence management products. Br J Nurs. May. 8–21. 2008;17(9):s12-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18567163].
1223 Dingwall L, McLafferty E. Do nurses promote urinary continence in hospitalized older people?: An exploratory study. J Clin Nurs. Oct. 2006;15(10):1276-86. Not eligible target population. [pmid: 16968432].
1224 Diokno A, Lee P, Zorn BH, et al. Factors associated with clinical assessment of overactive bladder and selection of treatment. Clin Ther. Sep. 2001;23(9):1542-51. no associative hypothesis tested. [pmid: 11589266].
1225 Diokno A, Yuhico M Jr. Preference, compliance and initial outcome of therapeutic options chosen by female patients with urinary incontinence. J Urol. Nov. 1995;154(5):1727-30. discussion 31. Not eligible outcomes. [pmid: 7563333].
1226 Diokno AC. Epidemiology and psychosocial aspects of incontinence. Urol Clin North Am. Aug. 1995;22(3):481-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7645150].
1227 Diokno AC, Burgio K, Fultz H, et al. Prevalence and outcomes of continence surgery in community dwelling women. J Urol. Aug. 2003;170(2 Pt 1):507-11. Not eligible exposure. [pmid: 12853810].
1228 Diokno AC, Burgio K, Fultz NH, et al. Medical and self-care practices reported by women with urinary incontinence. Am J Manag Care. Feb. 2004;10(2 Pt 1):69-78. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15011807].
1229 Diokno AC, Sand PK, Macdiarmid S, et al. Perceptions and behaviours of women with bladder control problems. Fam Pract. Oct. 2006;23(5):568-77. Not eligible exposure. [pmid: 16731545].
1230 Djaladat H, Mehrsai A, Saraji A, et al. Suprapubic prostatectomy with a novel catheter. J Urol. Jun. 2006;175(6):2083-6. Not eligible target population. [pmid: 16697808].
1231 Dmochowski RR. Management of postoperative overactive bladder complications. Geriatrics. May. 2002;57(Suppl 1):18-23. Not eligible exposure. [pmid: 12040599].
1232 Dmochowski RR. Treatment of the overactive bladder: where we stand in 2003. Rev Urol. 2003;5(Suppl 8):S11-7. Review. [pmid: 16985984].
1233 Dmochowski RR, Avon M, Ross J, et al. Transvaginal radio frequency treatment of the endopelvic fascia: a prospective evaluation for the treatment of genuine stress urinary incontinence. J Urol. Mar. 2003;169(3):1028-32. Not eligible exposure. [pmid: 12576838].
1234 Dmochowski RR, Sanders SW, Appell RA, et al. Bladder-health diaries: an assessment of 3-day vs 7-day entries. BJU Int. Nov. 2005;96(7):1049-54. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16225527].
1235 Dmochowski RR, Zimmern PE, Ganabathi K, et al. Role of the four-corner bladder neck suspension to correct stress incontinence with a mild to moderate cystocele. Urology. Jan. 1997;49(1):35-40. Not eligible exposure. [pmid: 9000182].
1236 Dobson P, David J. Developing integrated paediatric continence services. Nurs Times. Jan. 10–16. 2006;102(2):42-3. Not eligible target population. [pmid: 16429691].
1237 Dolan LM, Dixon WE, Hilton P. Urinary symptoms and quality of life in women following urogenital fistula repair: a long-term follow-up study. BJOG. Nov. 2008;115(12):1570-4. Not eligible exposure. [pmid: 19035993].
1238 Dolan LM, Walsh D, Hamilton S, et al. A study of quality of life in primigravidae with urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2004;15(3):160-4. Not eligible exposure. [pmid: 15167993].
1239 Dolman M. Continence. Remedial action. Nurs Times. Jun. 14–20. 1995;91(24):57-60. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7617487].
1240 Dolman M, Chase J. Comparison between the Health Belief Model and Subjective Expected Utility Theory: predicting incontinence prevention behaviour in post-partum women. J Eval Clin Pract. Aug. 1996;2(3):217-22. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9238593].
1241 Domingo S, Alama P, Ruiz N, et al. Transobturator tape procedure outcome: a clinical and quality of life analysis of a 1-year follow-up. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2007;18(8):895-900. Not eligible exposure. [pmid: 17136483].
1242 Dompeyre P, Fritel X, Bader G, et al. Bladder sensitivity testing using a visual analogue scale: comparative cystometric study on women. Neurourol Urodyn. 2007;26(3):350-5. Not eligible outcomes. [pmid: 17245770].
1243 Doody RS, Stevens JC, Beck C, et al. Practice parameter: management of dementia (an evidence-based review) Report of the Quality Standards Subcommittee of the American Academy of Neurology. Neurology. May. 8. 2001;56(9):1154-66. Not eligible target population. [pmid: 11342679].
1244 Dooley Y, Lowenstein L, Kenton K, et al. Mixed incontinence is more bothersome than pure incontinence subtypes. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2008;19(10):1359-62. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18491026].
1245 Dorey G, Feneley RC, Speakman MJ, et al. Pelvic floor muscle exercises and manometric biofeedback for erectile dysfunction and postmicturition dribble: three case studies. J Wound Ostomy Continence Nurs. Jan. 2003;30(1):44-51. discussion -2. Case report. [pmid: 12529593].
1246 Dorey G, Glazener C, Buckley B, et al. Developing a pelvic floor muscle training regimen for use in a trial intervention. Physiotherapy. Sep. 2009;95(3):199-209. Not eligible target population. [pmid: 19635340].
1247 Dorey G, Speakman M, Feneley R, et al. Pelvic floor exercises for treating post-micturition dribble in men with erectile dysfunction: a randomized controlled trial. Urologic Nursing. Dec. 490. 2004;24(6):512-7. Not eligible target population. [pmid: 21127].
1248 Dorflinger A, Gorton E, Stanton S, et al. Urethral pressure profile: is it affected by position?. Neurourol Urodyn. 2002;21(6):553-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12382246].
1249 Dosa D, Bowers B, Gifford DR. Critical review of resident assessment protocols. J Am Geriatr Soc. Apr. 2006;54(4):659-66. Not eligible target population. [pmid: 16686879].
1250 Doshani A, Pitchforth E, Mayne CJ, et al. Culturally sensitive continence care: a qualitative study among South Asian Indian women in Leicester. Fam Pract. Dec. 2007;24(6):585-93. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17962234].
1251 Dougherty M, Bishop K, Mooney R, et al. Graded pelvic muscle exercise. Effect on stress urinary incontinence. J Reprod Med. Sep. 1993;38(9):684-91. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8254589].
1252 Dougherty MC, Dwyer JW, Pendergast JF, et al. Community-based nursing: continence care for older rural women. Nurs Outlook. Sep–Oct. 1998;46(5):233-44. No associative hypothesis tested. [pmid: 9805343].
1253 Dowd T, Kolcaba K, Steiner R. Correlations among measures of bladder function and comfort. J Nurs Meas. Spring-Summer. 2002;10(1):27-38. Not eligible target population. [pmid: 12048966].
1254 Dowd T, Kolcaba K, Steiner R. The addition of coaching to cognitive strategies: interventions for persons with compromised urinary bladder syndrome. J Wound Ostomy Continence Nurs. Mar. 2003;30(2):90-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12658237].
1255 Dowell CJ, Bryant CM, Moore KH, et al. Calculating the direct costs of urinary incontinence: a new test instrument. BJU Int. Apr. 1999;83(6):596-606. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10233564].
1256 Downs TM, Sadetsky N, Pasta DJ, et al. Health related quality of life patterns in patients treated with interstitial prostate brachytherapy for localized prostate cancer--data from CaPSURE. J Urol. Nov. 2003;170(5):1822-7. Not eligible target population. [pmid: 14532784].
1257 Du C, Jin X, Bai F, et al. Holmium laser enucleation of the prostate: the safety, efficacy, and learning experience in China. J Endourol. May. 2008;22(5):1031-6. Not eligible target population. [pmid: 18377236].
1258 DuBeau CE. The continuum of urinary incontinence in an aging population. Geriatrics. May. 2002;57(Suppl 1):12-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12040598].
1259 DuBeau CE, Kiely DK, Resnick NM. Quality of life impact of urge incontinence in older persons: a new measure and conceptual structure. J Am Geriatr Soc. Aug. 1999;47(8):989-94. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10443861].
1260 DuBeau CE, Levy B, Mangione CM, et al. The impact of urge urinary incontinence on quality of life: importance of patients’ perspective and explanatory style. J Am Geriatr Soc. Jun. 1998;46(6):683-92. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9625182].
1261 DuBeau CE, Ouslander JG, Palmer MH. Knowledge and attitudes of nursing home staff and surveyors about the revised federal guidance for incontinence care. Gerontologist. Aug. 2007;47(4):468-79. Not eligible target population. [pmid: 17766668].
1262 Dubeau CE, Simon SE, Morris JN. The effect of urinary incontinence on quality of life in older nursing home residents. J Am Geriatr Soc. Sep. 2006;54(9):1325-33. Not eligible target population. [pmid: 16970638].
1263 Dubow JS. Autonomic dysfunction in Parkinson’s disease. Dis Mon. May. 2007;53(5):265-74. Not eligible target population. [pmid: 17656188].
1264 Duckett J, Patil A, Aggarwal I. The effect of duloxetine on urethral sphincter morphology. Ultrasound Obstet Gynecol. Feb. 2008;31(2):206-9. Case-series. [pmid: 18254135].
1265 Duckett JR, Aggarwal I, Patil A. Duloxetine treatment for women awaiting continence surgery. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2006;17(6):563-5. Case-series. [pmid: 16416257].
1266 Duckett JR, Tamilselvi A. Effect of tension-free vaginal tape in women with a urodynamic diagnosis of idiopathic detrusor overactivity and stress incontinence. BJOG. Jan. 2006;113(1):30-3. Not eligible exposure. [pmid: 16398768].
1267 Due U, Ottesen M. The Danish anal sphincter rupture questionnaire: validity and reliability. Acta Obstet Gynecol Scand. 2009;88(1):36-42. Not eligible target population. [pmid: 19023680].
1268 Dugan E, Cohen SJ, Bland DR, et al. The association of depressive symptoms and urinary incontinence among older adults. J Am Geriatr Soc. Apr. 2000;48(4):413-6. Not eligible target population. [pmid: 10798468].
1269 Dugan E, Cohen SJ, Robinson D, et al. The quality of life of older adults with urinary incontinence: determining generic and condition-specific predictors. Qual Life Res. May. 1998;7(4):337-44. Not eligible exposure. [pmid: 9610217].
1270 Dugan E, Roberts CP, Cohen SJ, et al. Why older community-dwelling adults do not discuss urinary incontinence with their primary care physicians. Journal of the American Geriatrics Society. Apr. 2001;49(4):462-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11347792].
1271 Duggan PM, Wilson PD, Norton P, et al. Utilization of preoperative urodynamic investigations by gynecologists who frequently operate for female urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2003;14(4):282-7. discussion 6–7. not eligible outcomes. [pmid: 14530842].
1272 Dull P. Transdermal oxybutynin (oxytrol) for urinary incontinence. Am Fam Physician. Dec. 15. 2004;70(12):2351-2. Comment. [pmid: 15617300].
1273 Dumoulin C, Bourbonnais D, Morin M, et al. Predictors of success for physiotherapy treatment in women with persistent postpartum stress urinary incontinence. Arch Phys Med Rehabil. Jul. 2010;91(7):1059-63. Not eligible target population. [pmid: 20537314].
1274 Dumoulin C, Korner-Bitensky N, Tannenbaum C. Urinary incontinence after stroke: identification, assessment, and intervention by rehabilitation professionals in Canada. Stroke. Oct. 2007;38(10):2745-51. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17823380].
1275 Dumoulin C, Seaborne DE, Quirion-DeGirardi C, et al. Pelvic-floor rehabilitation, Part 1: Comparison of two surface electrode placements during stimulation of the pelvic-floor musculature in women who are continent using bipolar interferential currents. Phys Ther. Dec. 1995;75(12):1067-74. Not eligible outcomes. [pmid: 7501709].
1276 Dumville JC, Manca A, Kitchener HC, et al. Cost-effectiveness analysis of open colposuspension versus laparoscopic colposuspension in the treatment of urodynamic stress incontinence. BJOG. Sep. 2006;113(9):1014-22. Not eligible exposure. [pmid: 16956333].
1277 Dunn JS Jr, Gruber D, Broberg J, et al. Urogynecology practice patterns among Air Force obstetricians and gynecologists: survey results. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2006;17(6):598-603. no associated hypothesis tested. [pmid: 16820999].
1278 Dwyer PL. Differentiating stress urinary incontinence from urge urinary incontinence. Int J Gynaecol Obstet. Jul. 2004;86(Suppl 1):S17-24. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15302564].
1279 Dwyer PL, Teele JS. Prazosin: a neglected cause of genuine stress incontinence. Obstet Gynecol. Jan. 1992;79(1):117-21. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 1727569].
1280 Easton BT. Is hormone replacement therapy (estrogen plus progestin) effective for the treatment of urinary incontinence in postmenopausal women?. J Fam Pract. May. 2001;50(5):470. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11350716].
1281 Ebrahim S, Patel N, Coats M, et al. Prevalence and severity of morbidity among Gujarati Asian elders: a controlled comparison. Fam Pract. Mar. 1991;8(1):57-62. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 2044874].
1282 Eckford SB, Kohler-Ockmore J, Feneley RC. Long-term follow-up of transvaginal urethral closure and suprapubic cystostomy for urinary incontinence in women with multiple sclerosis. Br J Urol. Sep. 1994;74(3):319-21. Not eligible exposure. [pmid: 7953263].
1283 Eckford SD, Jackson SR, Lewis PA, et al. The continence control pad--a new external urethral occlusion device in the management of stress incontinence. Br J Urol. Apr. 1996;77(4):538-40. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8777614].
1284 Edlund C, Dijkema HE, Hassouna MM, et al. Sacral nerve stimulation for refractory urge symptoms in elderly patients. Scand J Urol Nephrol. 2004;38(2):131-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15204397].
1285 Edlund C, Hellstrom M, Peeker R, et al. First Scandinavian experience of electrical sacral nerve stimulation in the treatment of the overactive bladder. Scand J Urol Nephrol. Dec. 2000;34(6):366-76. not eligible exposure. [pmid: 11195901].
1286 Edmunds A, Lethbridge Z. Appointing a continence consultant nurse. Nurs Stand. Oct. 4. 2000;15(3):40-1. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11971365].
1287 Edwall L, Carlstrom K, Jonasson AF. Markers of collagen synthesis and degradation in urogenital tissue from women with and without stress urinary incontinence. Neurourol Urodyn. 2005;24(4):319-24. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15924353].
1288 Edwall L, Carlstrom K, Jonasson AF. Endocrine status and markers of collagen synthesis and degradation in serum and urogenital tissue from women with and without stress urinary incontinence. Neurourol Urodyn. 2007;26(3):410-5. Not eligible exposure. [pmid: 17266139].
1289 Edwards DF, Hahn M, Dromerick A. Post stroke urinary loss, incontinence and life satisfaction: when does post-stroke urinary loss become incontinence?. Neurourol Urodyn. 2006;25(1):39-45. Not eligible target population. [pmid: 16299814].
1290 Edwards NI, Jones D. The prevalence of faecal incontinence in older people living at home. Age Ageing. Nov. 2001;30(6):503-7. Not eligible target population. [pmid: 11742780].
1291 Eekhof J, De Bock G, Schaapveld K, et al. Effects of screening for disorders among the elderly: an intervention study in general practice. Fam Pract. Aug. 2000;17(4):329-33. Not eligible target population. [pmid: 10934182].
1292 Ege E, Akin B, Altuntug K, et al. Prevalence of urinary incontinence in the 12-month postpartum period and related risk factors in Turkey. Urol Int. 2008;80(4):355-61. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18587244].
1293 Ehlert FJ, Griffin MT, Abe DM, et al. The M2 muscarinic receptor mediates contraction through indirect mechanisms in mouse urinary bladder. J Pharmacol Exp Ther. Apr. 2005;313(1):368-78. Not eligible population. [pmid: 15608083].
1294 Eilber KS. Stress Urinary Incontinence Following Transurethral Resection of the Prostate in Patients who have Undergone Radiation Therapy for Prostate Cancer. Paper presented at: 82nd Annual Meeting of the Western Section American Urological Association (MAUI 2006). Hyatt Regency, Maui, Hawaii (USA). 22–27 Oct 2006. Not eligible target population.
1295 Eisenberg ML, Elliott SP, McAninch JW. Preservation of lower urinary tract function in posterior urethral stenosis: selection of appropriate patients for urethral stents. J Urol. Dec. 2007;178(6):2456-60. discussion 60–1. Not eligible target population. [pmid: 17937962].
1296 Ek M, Tegerstedt G, Falconer C, et al. Urodynamic assessment of anterior vaginal wall surgery: a randomized comparison between colporraphy and transvaginal mesh. Neurourol Urodyn. Apr. 2010;29(4):527-31. Not eligible exposure. [pmid: 19731311].
1297 el Hemaly AK, Mousa LA. Stress urinary incontinence, a new concept. Eur J Obstet Gynecol Reprod Biol. Sep. 1996;68(1–2):129-35. Not eligible exposure. [pmid: 8886695].
1298 El-Azab AS, Mohamed EM, Sabra HI. The prevalence and risk factors of urinary incontinence and its influence on the quality of life among Egyptian women. Neurourol Urodyn. 2007;26(6):783-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17455273].
1299 El-Barky E, El-Shazly A, El-Wahab OA, et al. Tension free vaginal tape versus Burch colposuspension for treatment of female stress urinary incontinence. Int Urol Nephrol. 2005;37(2):277-81. Not eligible exposure. [pmid: 16142556].
1300 Elia G, Bergman A. Genuine stress urinary incontinence with low urethral pressure. Five-year follow-up after the Ball-Burch procedure. J Reprod Med. Jul. 1995;40(7):503-6. Not eligible exposure. [pmid: 7473438].
1301 Elkabir JJ, Mee AD. Long-term evaluation of the Gittes procedure for urinary stress incontinence. J Urol. Apr. 1998;159(4):1203-5. Not eligible exposure. [pmid: 9507834].
1302 Elkadry EA, Kenton KS, FitzGerald MP, et al. Patient-selected goals: a new perspective on surgical outcome. Am J Obstet Gynecol. Dec. 2003;189(6):1551-7. discussion 7–8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14710061].
1303 Ellerkmann RM, Dunn JS, McBride AW, et al. A comparison of anticipated pain before and pain rating after the procedure in patients who undergo cystourethroscopy. Am J Obstet Gynecol. Jul. 2003;189(1):66-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12861140].
1304 Ellerkmann RM, McBride AW, Dunn JS, et al. A comparison of anticipatory and postprocedure pain perception in patients who undergo urodynamic procedures. Am J Obstet Gynecol. Apr. 2004;190(4):1034-8. not eligible outcomes. [pmid: 15118637].
1305 Ellsworth PI, Webb HW, Crump JM, et al. The Malone antegrade colonic enema enhances the quality of life in children undergoing urological incontinence procedures. J Urol. Apr. 1996;155(4):1416-8. Not eligible target population. [pmid: 8632601].
1306 Elmer C, Altman D, Engh ME, et al. Trocar-guided transvaginal mesh repair of pelvic organ prolapse. Obstet Gynecol. Jan. 2009;113(1):117-26. Not eligible exposure. [pmid: 19104367].
1307 el-Sayed RF, Morsy MM, el-Mashed SM, et al. Anatomy of the urethral supporting ligaments defined by dissection, histology, and MRI of female cadavers and MRI of healthy nulliparous women. AJR Am J Roentgenol. Nov. 2007;189(5):1145-57. Not eligible exposure. [pmid: 17954653].
1308 Elser DM, Mitchell GK, Miklos JR, et al. Nonsurgical transurethral collagen denaturation for stress urinary incontinence in women: 12-month results from a prospective long-term study. Journal of Minimally Invasive Gynecology. Jan–Feb. 2009;16(1):56-62. 21036. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 19013110].
1309 Elzevier HW, Putter H, Delaere KP, et al. Female sexual function after surgery for stress urinary incontinence: transobturator suburethral tape vs. tension-free vaginal tape obturator. J Sex Med. Feb. 2008;5(2):400-6. Not eligible exposure. [pmid: 18042216].
1310 Elzevier HW, Venema PL, Lycklama a Nijeholt AA. Sexual function after tension-free vaginal tape (TVT) for stress incontinence: results of a mailed questionnaire. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2004;15(5):313-8. Not eligible exposure. [pmid: 15278249].
1311 Emberton M, Neal DE, Black N, et al. The effect of prostatectomy on symptom severity and quality of life. Br J Urol. Feb. 1996;77(2):233-47. Not eligible target population. [pmid: 8800892].
1312 Engberg S, McDowell BJ, Donovan N, et al. Treatment of urinary incontinence in homebound older adults: interface between research and practice. Ostomy Wound Manage. Nov–Dec. 1997;43(10):18-22. 4. 6. No primary results. [pmid: 9460431].
1313 Engberg S, McDowell BJ, Weber E, et al. Assessment and management of urinary incontinence among homebound older adults: a clinical trial protocol. Adv Pract Nurs Q. Fall. 1997;3(2):48-56. No association/hypothesis tested. [pmid: 9432453].
1314 Engberg S, Sereika S, Weber E, et al. Prevalence and recognition of depressive symptoms among homebound older adults with urinary incontinence. J Geriatr Psychiatry Neurol. Fall. 2001;14(3):130-9. Not eligible outcomes. [pmid: 11563436].
1315 Engstrom G, Henningsohn L, Steineck G, et al. Self-assessed health, sadness and happiness in relation to the total burden of symptoms from the lower urinary tract. BJU Int. 2005;95:810-5. Not eligible outcomes. [pmid: 15794788].
1316 Engstrom G, Henningsohn L, Walker-Engstrom ML, et al. Impact on quality of life of different lower urinary tract symptoms in men measured by means of the SF 36 questionnaire. Scand J Urol Nephrol. 2006;40(6):485-94. Not eligible target population. [pmid: 17130101].
1317 Engstrom G, Walker-Engstrom ML, Henningsohn L, et al. Prevalence of distress and symptom severity from the lower urinary tract in men: a population-based study with the DAN-PSS questionnaire. Fam Pract. Dec. 2004;21(6):617-22. Not eligible target population. [pmid: 15465878].
1318 Enzelsberger H, Helmer H, Schatten C. Comparison of Burch and lyodura sling procedures for repair of unsuccessful incontinence surgery. Obstet Gynecol. Aug. 1996;88(2):251-6. Not eligible exposure. [pmid: 8692511].
1319 Enzelsberger H, Kurz C, Helmer H, et al. Effects of topical oxybutynin chloride in women with dysfunctional bladders: Results of a double blind placebo-controlled study. <ORIGINAL> ZUR TOPISCHEN ANWENDUNG VON OXYBUTYNINHYDROCHLORID BEI FRAUEN MIT URGE-INKONTINENZ. ERGEBNISSE EINER PROSPEKTIV RANDOMISIERTEN DOPPELBLINDSTUDIE. Geburtshilfe Und Frauenheilkunde. 1995;(5):240-3. Language. [pmid: 7607378].
1320 Enzelsberger H, Schatten C, Kurz C. Comparison of emepronium bromide and intravesically administered lidocain gel in the management of females with urge incontinence. Geburtshilfe Frauenheilkd. 1991:54-7. Not eligible exposure. [pmid: 2026301].
1321 Epstein LB, Graham CA, Heit MH. Correlation between vaginal stiffness index and pelvic floor disorder quality-of-life scales. Int Urogynecol J Pelvic Floor Dysfunct. Jul. 2008;19(7):1013-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18217178].
1322 Ercolano E. Follow up of men post-prostatectomy: who is responsible?. Urol Nurs. Oct. 2008;28(5):370-7. discussion 8–80. Not eligible target population. [pmid: 18980103].
1323 Erdinc A, Gurates B, Celik H, et al. The efficacy of venlafaxine in the treatment of women with stress urinary incontinence. Arch Gynecol Obstet. Mar. 2009;279(3):343-8. Not eligible exposure. [pmid: 18629526].
1324 Espuna Pons M, Puig Clota M. Coital urinary incontinence: impact on quality of life as measured by the King’s Health Questionnaire. Int Urogynecol J Pelvic Floor Dysfunct. May. 2008;19(5):621-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17973067].
1325 Espuna-Pons M, Rebollo P, Puig-Clota M, et al. Eliciting Women’s Preferences for Treatment of Stress Urinary Incontinence with the Method of Paired Comparison. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Not eligible outcomes.
1326 Ethans KD, Nance PW, Bard RJ, et al. Efficacy and safety of tolterodine in people with neurogenic detrusor overactivity. J Spinal Cord Med. 2004;27(3):214-8. Not eligible target population. [pmid: 15478523].
1327 Etheridge F, Tannenbaum C, Couturier Y. A systemwide formula for continence care: overcoming barriers, clarifying solutions, and defining team members’ roles. J Am Med Dir Assoc. Mar. 2008;9(3):178-89. Not eligible exposure. [pmid: 18294601].
1328 Evans A, Pheby D, Painter D, et al. The costs of long-term catheterization in the community. Br J Community Nurs. Oct. 2000;5(10):477-8. 80. 82. 84. 8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12181515].
1329 Evans D. Lifestyle solutions for men with continence problems. Nurs Times. Jan. 11–17. 2005;101(2):61-2. 4. Case report. [pmid: 15688925].
1330 Evans D. Discreet products for women with urinary incontinence. Nurs Times. May. 3–9. 2005;101(18):56-7. 9. Case report. [pmid: 15892508].
1331 Everaert K, De Ridder D, Baert L, et al. Patient satisfaction and complications following sacral nerve stimulation for urinary retention, urge incontinence and perineal pain: a multicenter evaluation. Int Urogynecol J Pelvic Floor Dysfunct. 2000;11(4):231-5. discussion 6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11005475].
1332 Ewings P, Spencer S, Marsh H, et al. Obstetric risk factors for urinary incontinence and preventative pelvic floor exercises: cohort study and nested randomized controlled trial. J Obstet Gynaecol. Aug. 2005;25(6):558-64. Not eligible target population. [pmid: 16234140].
1333 Fader M, Clarke-O’Neill S, Cook D, et al. Management of night-time urinary incontinence in residential settings for older people: an investigation into the effects of different pad changing regimes on skin health. J Clin Nurs. May. 2003;12(3):374-86. not eligible outcomes. [pmid: 12709112].
1334 Fader M, Macaulay M, Pettersson L, et al. A multi-centre evaluation of absorbent products for men with light urinary incontinence. Neurourol Urodyn. 2006;25(7):689-95. Not eligible target population. [pmid: 17009303].
1335 Fader M, Moore KN, Cottenden AM, et al. Coated catheters for intermittent catheterization: smooth or sticky?. BJU Int. Sep. 2001;88(4):373-7. Not eligible exposure. [pmid: 11564024].
1336 Fader M, Pettersson L, Dean G, et al. Sheaths for urinary incontinence: a randomized crossover trial. BJU Int. Sep. 2001;88(4):367-72. Not eligible target population. [pmid: 11564023].
1337 Falconer C, Ekman G, Malmstrom A, et al. Decreased collagen synthesis in stress-incontinent women. Obstet Gynecol. Oct. 1994;84(4):583-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8090397].
1338 Falconer C, Ekman-Ordeberg G, Blomgren B, et al. Paraurethral connective tissue in stress-incontinent women after menopause. Acta Obstet Gynecol Scand. Jan. 1998;77(1):95-100. Not eligible exposure. [pmid: 9492727].
1339 Fantl JA, Cardozo L, McClish DK. Estrogen therapy in the management of urinary incontinence in postmenopausal women: a meta-analysis. First report of the Hormones and Urogenital Therapy Committee. Obstet Gynecol. Jan. 1994;83(1):12-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8272292].
1340 Faria CA, Sartori MG, Baracat EC, et al. Effects of tamoxifen on Doppler velocimetry parameters of periurethral vessels in postmenopausal women. Int Urogynecol J Pelvic Floor Dysfunct. Jan–Feb. 2005;16(1):56-9. discussion 9. Not eligible target population. [pmid: 15338114].
1341 Farrell KD, Robinson LM, Baydock SA, et al. A survey of Canadian websites providing information about female urinary incontinence. J Obstet Gynaecol Can. Aug. 2006;28(8):700-12. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17022910].
1342 Farrell SA, Baskett TF, Baydock S. The use of intraoperative cystoscopy by general gynaecologists in Canada. J Obstet Gynaecol Can. Jan. 2009;31(1):48-53. Not eligible exposure. [pmid: 19208283].
1343 Farrell SA, Epp A, Flood C, et al. The evaluation of stress incontinence prior to primary surgery. Journal of Obstetrics & Gynaecology Canada: JOGC. Apr. 2003;25(4):313-24. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 21130].
1344 Fatthy H, El Hao M, Samaha I, et al. Modified Burch colposuspension: laparoscopy versus laparotomy. J Am Assoc Gynecol Laparosc. Feb. 2001;8(1):99-106. Not eligible exposure. [pmid: 11172123].
1345 Feigenberg SJ, Lee WR, Desilvio ML, et al. Health-related quality of life in men receiving prostate brachytherapy on RTOG 98-05. Int J Radiat Oncol Biol Phys. Jul. 15. 2005;62(4):956-64. Not eligible target population. [pmid: 15989995].
1346 Feldman EL, Jaffe A, Galambos N, et al. Clinical practice guidelines on depression: awareness, attitudes, and content knowledge among family physicians in New York. Arch Fam Med. Jan–Feb. 1998;7(1):58-62. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9443701].
1347 Feneley RC, Parkin J, Scanlan J, et al. Developing alternative devices to the long-term urinary catheter for draining urine from the bladder. Proc Inst Mech Eng [H]. 2003;217(4):297-303. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12885200].
1348 Fenner DE, Genberg B, Brahma P, et al. Fecal and urinary incontinence after vaginal delivery with anal sphincter disruption in an obstetrics unit in the United States. Am J Obstet Gynecol. Dec. 2003;189(6):1543-9. discussion 9–50. Not eligible target population. [pmid: 14710059].
1349 Ferrer M, Suarez JF, Guedea F, et al. Health-related quality of life 2 years after treatment with radical prostatectomy, prostate brachytherapy, or external beam radiotherapy in patients with clinically localized prostate cancer. Int J Radiat Oncol Biol Phys. Oct. 1. 2008;72(2):421-32. Not eligible target population. [pmid: 18325680].
1350 Festen L, Duggan P, Coates D. Improved quality of life in women treated for urinary incontinence by an authorised continence nurse practitioner. Int Urogynecol J Pelvic Floor Dysfunct. Apr. 2008;19(4):567-71. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17898919].
1351 Fialkow MF, Melville JL, Lentz GM, et al. The functional and psychosocial impact of fecal incontinence on women with urinary incontinence. Am J Obstet Gynecol. Jul. 2003;189(1):127-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12861150].
1352 Ficarra V, Novara G, Galfano A, et al. Twelve-month self-reported quality of life after retropubic radical prostatectomy: a prospective study with Rand 36-Item Health Survey (Short Form-36). BJU Int. Feb. 2006;97(2):274-8. Not eligible target population. [pmid: 16430628].
1353 Filbeck T, Ullrich T, Pichlmeier U, et al. Correlation of persistent stress urinary incontinence with quality of life after suspension procedures: is continence the only decisive postoperative criterion of success?. Urology. Aug. 1999;54(2):247-51. Not eligible exposure. [pmid: 10443719].
1354 Filocamo MT, Li Marzi V, Del Popolo G, et al. Effectiveness of early pelvic floor rehabilitation treatment for post-prostatectomy incontinence. Eur Urol. Nov. 2005;48(5):734-8. Not eligible target population. [pmid: 16002204].
1355 Filocamo MT, Li Marzi V, Del Popolo G, et al. Pharmacologic treatment in postprostatectomy stress urinary incontinence. European urology. Jun. 2007;51(6):1559-64. Not eligible target population. [pmid: 16942833].
1356 Finazzi-Agro E, Rocchi C, Pachatz C, et al. Percutaneous tibial nerve stimulation produces effects on brain activity: study on the modifications of the long latency somatosensory evoked potentials. Neurourol Urodyn. 2009;28(4):320-4. NE outcomes. [pmid: 19090588].
1357 Fink HA, Taylor BC, Tacklind JW, et al. Treatment interventions in nursing home residents with urinary incontinence: a systematic review of randomized trials. Mayo Clin Proc. Dec. 2008;83(12):1332-43. Not eligible target population. [pmid: 19046552].
1358 Finkelstein MM, Skelly J, Kaczorowski J, et al. Incontinence Quality of Life Instrument in a survey of primary care physicians. J Fam Pract. Nov. 2002;51(11):952. Not eligible target population. [pmid: 12485550].
1359 Finlayson TL, Moyer CA, Sonnad SS. Assessing symptoms, disease severity, and quality of life in the clinical context: a theoretical framework. Am J Manag Care. May. 2004;10(5):336-44. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15152704].
1360 Finne-Soveri H, Sorbye LW, Jonsson PV, et al. Increased work-load associated with faecal incontinence among home care patients in 11 European countries. Eur J Public Health. Jun. 2008;18(3):323-8. Not eligible target population. [pmid: 17766995].
1361 Fiori M, Gunelli R, Mercuriali M, et al. Tension-free vaginal tape and female stress incontinence: further evidence of effectiveness. Urol Int. 2004;72(4):325-8. Not eligible exposure. [pmid: 15153731].
1362 Fischer A, Fink T, Zachmann S, et al. Comparison of retropubic and outside-in transoburator sling systems for the cure of female genuine stress urinary incontinence. Eur Urol. Nov. 2005;48(5):799-804. Not eligible exposure. [pmid: 16140455].
1363 Fitzgerald MP, Ayuste D, Brubaker L. How do urinary diaries of women with an overactive bladder differ from those of asymptomatic controls?. BJU Int. Aug. 2005;96(3):365-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16042731].
1364 FitzGerald MP, Butler N, Shott S, et al. Bother arising from urinary frequency in women. Neurourol Urodyn. 2002;21(1):36-40. discussion 1. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11835422].
1365 FitzGerald MP, Elliott C, Brubaker L. New vs old: descriptors can affect patients’ surgical preferences. Am J Obstet Gynecol. Nov. 2008;199(5):476 e1-3. Not eligible exposure. [pmid: 18468572].
1366 FitzGerald MP, Kenton K, Shott S, et al. Responsiveness of quality of life measurements to change after reconstructive pelvic surgery. Am J Obstet Gynecol. Jul. 2001;185(1):20-4. Not eligible exposure. [pmid: 11483898].
1367 FitzGerald MP, Mollenhauer J, Brubaker L. The fate of rectus fascia suburethral slings. Am J Obstet Gynecol. Oct. 2000;183(4):964-6. Not eligible exposure. [pmid: 11035347].
1368 Fitzgerald MP, Richter HE, Bradley CS, et al. Pelvic support, pelvic symptoms, and patient satisfaction after colpocleisis. International Urogynecology Journal. Dec. 2008;19(12):1603-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 21038].
1369 Fitzgerald MP, Thom DH, Wassel-Fyr C, et al. Childhood urinary symptoms predict adult overactive bladder symptoms. J Urol. Mar. 2006;175(3 Pt 1):989-93. Not eligible target population. [pmid: 16469599].
1370 Fitzgerald ST, Palmer MH, Kirkland VL, et al. The impact of urinary incontinence in working women: a study in a production facility. Women Health. 2002;35(1):1-16. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11942466].
1371 Flaherty JH, Miller DK, Coe RM. Impact on caregivers of supporting urinary function in noninstitutionalized, chronically ill seniors. Gerontologist. Aug. 1992;32(4):541-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 1427258].
1372 Fleshner N, Herschorn S. The artificial urinary sphincter for post-radical prostatectomy incontinence: impact on urinary symptoms and quality of life. J Urol. Apr. 1996;155(4):1260-4. Not eligible target population. [pmid: 8632546].
1373 Floratos DL, Sonke GS, Rapidou CA, et al. Biofeedback vs verbal feedback as learning tools for pelvic muscle exercises in the early management of urinary incontinence after radical prostatectomy. BJU Int. May. 2002;89(7):714-9. Not eligible target population. [pmid: 11966630].
1374 Foglia G, Mistrangelo E, Lijoi D, et al. Transfascial vaginal tape (TFT): a simple, safe and cost-effective procedure for stress urinary incontinence. A preliminary study. Arch Gynecol Obstet. Jul. 2007;276(1):59-63. Not eligible exposure. [pmid: 17219162].
1375 Foldspang A, Mommsen S. The International Continence Society (ICS) incontinence definition: is the social and hygienic aspect appropriate for etiologic research?. J Clin Epidemiol. Sep. 1997;50(9):1055-60. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9363040].
1376 Fonda D, Woodward M, D’Astoli M, et al. Sustained improvement of subjective quality of life in older community-dwelling people after treatment of urinary incontinence. Age Ageing. Jul. 1995;24(4):283-6. Not eligible target population. [pmid: 7484483].
1377 Fontaine E, Ben Mouelli S, Thomas L, et al. Urinary continence after salvage radiation therapy following radical prostatectomy, assessed by a self-administered questionnaire: a prospective study. BJU Int. Sep. 2004;94(4):521-3. Not eligible target population. [pmid: 15329104].
1378 Fontaine E, Hajri M, Rhein F, et al. Reappraisal of endoscopic sphincterotomy for post-traumatic neurogenic bladder: a prospective study. J Urol. Jan. 1996;155(1):277-80. Not eligible exposure. [pmid: 7490855].
1379 Foote AJ, Maughan V, Carne C. Laparoscopic colposuspension versus vaginal suburethral slingplasty: a randomised prospective trial. Aust N Z J Obstet Gynaecol. Dec. 2006;46(6):517-20. Not eligible exposure. [pmid: 17116057].
1380 Foote AJ, Moore KH. The cost of urogynaecological treatments: which are more cost-effective?. Aust N Z J Obstet Gynaecol. Jun. 2007;47(3):240-6. Not eligible exposure. [pmid: 17550494].
1381 Forbat L. Listening to carers talking about the subjects of continence and toileting. Nurs Times. Jan. 13–19. 2004;100(2):46-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14768154].
1382 Forbes A, While A, Mathes L, et al. Health problems and health-related quality of life in people with multiple sclerosis. Clin Rehabil. Jan. 2006;20(1):67-78. Not eligible target population. [pmid: 16502752].
1383 Forster JA, Thomas WM. Patient preferences and side effects experienced with oral bowel preparations versus self-administered phosphate enema. Ann R Coll Surg Engl. May. 2003;85(3):185-6. Not eligible target population. [pmid: 12831492].
1384 Foster RT Sr., Anoia EJ, Webster GD, et al. In patients undergoing neuromodulation for intractable urge incontinence a reduction in 24-hr pad weight after the initial test stimulation best predicts long-term patient satisfaction. Neurourol Urodyn. 2007;26(2):213-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17009252].
1385 Fowler FJ Jr, Barry MJ, Lu-Yao G, et al. Effect of radical prostatectomy for prostate cancer on patient quality of life: results from a Medicare survey. Urology. Jun. 1995;45(6):1007-13. discussion 13–5. Not eligible target population. [pmid: 7771002].
1386 Fowler FJ Jr, Barry MJ, Lu-Yao G, et al. Outcomes of external-beam radiation therapy for prostate cancer: a study of Medicare beneficiaries in three surveillance, epidemiology, and end results areas. J Clin Oncol. Aug. 1996;14(8):2258-65. Not eligible target population. [pmid: 8708715].
1387 Fox PD, Coleman E. Managing common geriatric conditions. Healthplan. Mar–Apr. 2002;43(2):47-53. Not eligible exposure. [pmid: 11961924].
1388 Foxman B, Somsel P, Tallman P, et al. Urinary tract infection among women aged 40 to 65: behavioral and sexual risk factors. J Clin Epidemiol. Jul. 2001;54(7):710-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11438412].
1389 Franco I, Landau-Dyer L, Isom-Batz G, et al. The use of botulinum toxin A injection for the management of external sphincter dyssynergia in neurologically normal children. Journal of Urology. discussion 1779–80. Oct. 2007;178(4 Pt 2):1775-9. Not eligible target population. [pmid: 17707430].
1390 Franco N, Shobeiri SA, Echols KT. Medium-term follow-up of transvaginal suburethral slings: variance in outcome success using two different evaluation methods. Urology. Oct. 2002;60(4):607-10. discussion 10–1. Not eligible exposure. [pmid: 12385917].
1391 Frank SJ, Pisters LL, Davis J, et al. An assessment of quality of life following radical prostatectomy, high dose external beam radiation therapy and brachytherapy iodine implantation as monotherapies for localized prostate cancer. J Urol. Jun. 2007;177(6):2151-6. discussion 6. Not eligible target population. [pmid: 17509305].
1392 Franke JJ, Gilbert WB, Grier J, et al. Early post-prostatectomy pelvic floor biofeedback. J Urol. Jan. 2000;163(1):191-3. Not eligible target population. [pmid: 10604344].
1393 Frankenburg FR, Zanarini MC. The association between borderline personality disorder and chronic medical illnesses, poor health-related lifestyle choices, and costly forms of health care utilization. J Clin Psychiatry. Dec. 2004;65(12):1660-5. Not eligible target population. [pmid: 15641871].
1394 Fransson P. Patient-reported lower urinary tract symptoms, urinary incontinence, and quality of life after external beam radiotherapy for localized prostate cancer--15 years’ follow-up. A comparison with age-matched controls. Acta Oncol. 2008;47(5):852-61. Not eligible target population. [pmid: 17899451].
1395 Fransson P, Damber JE, Tomic R, et al. Quality of life and symptoms in a randomized trial of radiotherapy versus deferred treatment of localized prostate carcinoma. Cancer. Dec. 15. 2001;92(12):3111-9. Not eligible target population. [pmid: 11753990].
1396 Frantz RA, Xakellis GC Jr, Harvey PC, et al. Implementing an incontinence management protocol in long-term care. Clinical outcomes and costs. J Gerontol Nurs. Aug. 2003;29(8):46-53. Not eligible target population. [pmid: 13677160].
1397 Frederick RW, Leach GE. Cadaveric prolapse repair with sling: intermediate outcomes with 6 months to 5 years of followup. J Urol. Apr. 2005;173(4):1229-33. Not eligible exposure. [pmid: 15758758].
1398 Freeman RM. The role of pelvic floor muscle training in urinary incontinence. BJOG: An International Journal of Obstetrics and Gynaecology. 2004;111(SUPPL 1):37-40. Review. [pmid: 15663155].
1399 Freeman RM, Adekanmi O, Waterfield MR, et al. The effect of cannabis on urge incontinence in patients with multiple sclerosis: a multicentre, randomised placebo-controlled trial (CAMS-LUTS). Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2006;17(6):636-41. Not eligible target population. [pmid: 16552618].
1400 Freundl M, Dugan J. Urinary incontinence in the elderly: knowledge and attitude of long-term care staff. Geriatr Nurs. Mar–Apr. 1992;13(2):70-5. Not eligible target population. [pmid: 1321083].
1401 Friedman SM, Steinwachs DM, Rathouz PJ, et al. Characteristics predicting nursing home admission in the program of all-inclusive care for elderly people. Gerontologist. Apr. 2005;45(2):157-66. Not eligible exposure. [pmid: 15799980].
1402 Frimberger D, Gearhart JP, Mathews R. Female exstrophy: failure of initial reconstruction and its implications for continence. J Urol. Dec. 2003;170(6 Pt 1):2428-31. Not eligible target population. [pmid: 14634445].
1403 Frimberger D, Lakshmanan Y, Gearhart JP. Continent urinary diversions in the exstrophy complex: why do they fail?. J Urol. Oct. 2003;170(4 Pt 1):1338-42. Not eligible target population. [pmid: 14501765].
1404 Fritel X, Schaal JP, Fauconnier A, et al. Pelvic floor disorders 4 years after first delivery: a comparative study of restrictive versus systematic episiotomy. BJOG. Jan. 2008;115(2):247-52. Not eligible exposure. [pmid: 17970794].
1405 Fu X, Rezapour M, Wu X, et al. Expression of estrogen receptor-alpha and -beta in anterior vaginal walls of genuine stress incontinent women. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2003;14(4):276-81. discussion 81. not eligible outcomes. [pmid: 14530841].
1406 Fulmer BR, Bissonette EA, Petroni GR, et al. Prospective assessment of voiding and sexual function after treatment for localized prostate carcinoma: comparison of radical prostatectomy to hormonobrachytherapy with and without external beam radiotherapy. Cancer. Jun. 1. 2001;91(11):2046-55. Not eligible target population. [pmid: 11391584].
1407 Fultz NH, Burgio K, Diokno AC, et al. Burden of stress urinary incontinence for community-dwelling women. Am J Obstet Gynecol. Nov. 2003;189(5):1275-82. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14634553].
1408 Fultz NH, Fisher GG, Jenkins KR. Does urinary incontinence affect middle-aged and older women’s time use and activity patterns?. Obstet Gynecol. Dec. 2004;104(6):1327-34. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15572498].
1409 Fultz NH, Herzog AR. Self-reported social and emotional impact of urinary incontinence. J Am Geriatr Soc. Jul. 2001;49(7):892-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11527480].
1410 Fultz NH, Rahrig Jenkins K, Ostbye T, et al. The impact of own and spouse’s urinary incontinence on depressive symptoms. Soc Sci Med. Jun. 2005;60(11):2537-48. Not eligible exposure. [pmid: 15814179].
1411 Furst CJ. Radiotherapy for cancer. Quality of life. Acta Oncol. 1996;35(Suppl 7):141-8. Not eligible target population. [pmid: 9154107].
1412 Furuta A, Jankowski RJ, Pruchnic R, et al. Physiological effects of human muscle-derived stem cell implantation on urethral smooth muscle function. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2008;19(9):1229-34. Not eligible target population. [pmid: 18421407].
1413 Gaines KK. Trospium chloride (Sanctura)--new to the U.S. for overactive bladder. Urol Nurs. Feb. 2005;25(1):64-5. 52. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15779697].
1414 Galarneau L. Continence in the community. Perspectives. Fall. 2008;32(3):17-21. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 19180939].
1415 Gallagher BL, Dwyer NT, Gaynor-Krupnick DM, et al. Objective and quality-of-life outcomes with bone-anchored male bulbourethral sling. Urology. Jun. 2007;69(6):1090-4. Not eligible target population. [pmid: 17572193].
1416 Gallagher S. Marketing a hospital-based specialty program. J Wound Ostomy Continence Nurs. Jul. 1995;22(4):173-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7627291].
1417 Gallo M, Staskin DR. Patient satisfaction with a reusable undergarment for urinary incontinence. J Wound Ostomy Continence Nurs. Jul. 1997;24(4):226-36. Not eligible target population. [pmid: 9274280].
1418 Gallo ML, Fallon PJ. Evaluation of a pelvic floor treatment plan for patients undergoing radical prostatectomy. Urol Nurs. Mar. 1996;16(1):9-13. Not eligible target population. [pmid: 8826389].
1419 Galloway NT, El-Galley RE, Sand PK, et al. Extracorporeal magnetic innervation therapy for stress urinary incontinence. Urology. Jun. 1999;53(6):1108-11. Level of evidence. [pmid: 10367836].
1420 Gallucci M, Puppo P, Perachino M, et al. Transurethral electrovaporization of the prostate vs. transurethral resection. Results of a multicentric, randomized clinical study on 150 patients. Eur Urol. 1998;33(4):359-64. Not eligible target population. [pmid: 9612677].
1421 Game X, Castel-Lacanal E, Bentaleb Y, et al. Botulinum toxin A detrusor injections in patients with neurogenic detrusor overactivity significantly decrease the incidence of symptomatic urinary tract infections. Eur Urol. Mar. 2008;53(3):613-8. Not eligible target population. [pmid: 17804150].
1422 Ganatra HA, Zafar SN, Qidwai W, et al. Prevalence and predictors of depression among an elderly population of Pakistan. Aging Ment Health. May. 2008;12(3):349-56. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18728948].
1423 Ganta SB, Chakravarti A, Somani B, et al. Removal of catheter at midnight versus early morning: the patients’ perspective. Urol Int. 2005;75(1):26-9. Not eligible target population. [pmid: 16037704].
1424 Ganz PA, Desmond KA, Leedham B, et al. Quality of life in long-term, disease-free survivors of breast cancer: a follow-up study. J Natl Cancer Inst. Jan. 2. 2002;94(1):39-49. Not eligible target population. [pmid: 11773281].
1425 Ganz PA, Greendale GA, Kahn B, et al. Are older breast carcinoma survivors willing to take hormone replacement therapy?. Cancer. Sep. 1. 1999;86(5):814-20. Not eligible target population. [pmid: 10463980].
1426 Ganz PA, Greendale GA, Petersen L, et al. Managing menopausal symptoms in breast cancer survivors: results of a randomized controlled trial. J Natl Cancer Inst. Jul. 5. 2000;92(13):1054-64. Not eligible target population. [pmid: 10880548].
1427 Gardner BG, Zietman AL, Shipley WU, et al. Late normal tissue sequelae in the second decade after high dose radiation therapy with combined photons and conformal protons for locally advanced prostate cancer. J Urol. Jan. 2002;167(1):123-6. Not eligible target population. [pmid: 11743288].
1428 Garley A, Unwin J. A case series to pilot cognitive behaviour therapy for women with urinary incontinence. Br J Health Psychol. Sep. 2006;11(Pt 3):373-86. Case-series. [pmid: 16870050].
1429 Gasquet I, Tcherny-Lessenot S, Gaudebout P, et al. Influence of the severity of stress urinary incontinence on quality of life, health care seeking, and treatment: A national cross-sectional survey. Eur Urol. Oct. 2006;50(4):818-25. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16678340].
1430 Gateau T, Faramarzi-Roques R, Le Normand L, et al. Clinical and urodynamic repercussions after TVT procedure and how to diminish patient complaints. Eur Urol. Sep. 2003;44(3):372-6. discussion 6. Not eligible exposure. [pmid: 12932939].
1431 Gearhart SL, Pannu HK, Cundiff GW, et al. Perineal descent and levator ani hernia: a dynamic magnetic resonance imaging study. Dis Colon Rectum. Aug. 2004;47(8):1298-304. Not eligible target population. [pmid: 15484342].
1432 Geary ES, Dendinger TE, Freiha FS, et al. Nerve sparing radical prostatectomy: a different view. J Urol. Jul. 1995;154(1):145-9. Not eligible target population. [pmid: 7776409].
1433 Gebhart JB, Dixon DA, Trabuco EC, et al. Three-year outcomes of Uretex Urethral Support System for treatment of stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2008;19(8):1075-9. Not eligible exposure. [pmid: 18305884].
1434 Gee WF, Holtgrewe HL, Albertsen PC, et al. Practice trends of American urologists in the treatment of impotence, incontinence and infertility. J Urol. Nov. 1996;156(5):1778-80. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8863607].
1435 Geller EJ, Barbee ER, Wu JM, et al. Validation of telephone administration of 2 condition-specific quality-of-life questionnaires. Am J Obstet Gynecol. Dec. 2007;197(6):632 e1-4. Not eligible outcomes. [pmid: 18060958].
1436 German KA, Kynaston H, Weight S, et al. A prospective randomized trial comparing a modified needle suspension procedure with the vagina/obturator shelf procedure for genuine stress incontinence. Br J Urol. Aug. 1994;74(2):188-90. Not eligible exposure. [pmid: 7921936].
1437 Gerten KA, Richter HE, Burgio KL, et al. Impact of urinary incontinence in morbidly obese women versus women seeking urogynecologic care. Urology. Dec. 2007;70(6):1082-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18158022].
1438 Getliffe K, Fader M, Cottenden A, et al. Absorbent products for incontinence: ‘treatment effects’ and impact on quality of life. J Clin Nurs. Oct. 2007;16(10):1936-45. No associative hypothesis tested. [pmid: 17880482].
1439 Ghali WA, Freund KM, Boss RD, et al. Menopausal hormone therapy: physician awareness of patient attitudes. Am J Med. Jul. 1997;103(1):3-10. Not eligible exposure. [pmid: 9236479].
1440 Ghaly M, Wallner K, Merrick G, et al. The effect of supplemental beam radiation on prostate brachytherapy-related morbidity: morbidity outcomes from two prospective randomized multicenter trials. Int J Radiat Oncol Biol Phys. Apr. 1. 2003;55(5):1288-93. Not eligible target population. [pmid: 12654439].
1441 Ghei M, Nathan S, Maraj BH, et al. A day case technique for administration of intradetrusor Botulinum toxin B under sedo-analgesia in neuropathic and non-neuropathic detrusor overactivity: Endoscopic Neurostabilisation (ENS). Int Urol Nephrol. 2005;37(3):471-2. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16307321].
1442 Ghoniem G, Corcos J, Comiter C, et al. Durability of urethral bulking agent injection for female stress urinary incontinence: 2-year multicenter study results. J Urol. Apr. 2010;183(4):1444-9. level of evidence. [pmid: 20171691].
1443 Ghoniem GM. The recalcitrant overactive bladder patient. Geriatrics. May. 2002;57(Suppl 1):23-9. Not eligible exposure. [pmid: 12040600].
1444 Ghoniem GM, Bryan W. Male perineal sling. Tech Urol. Sep. 2001;7(3):229-32. Not eligible target population. [pmid: 11575520].
1445 Giannantoni A, Di Stasi SM, Stephen RL, et al. Intravesical capsaicin versus resiniferatoxin in patients with detrusor hyperreflexia: a prospective randomized study. J Urol. Apr. 2002;167(4):1710-4. Not eligible target population. [pmid: 11912393].
1446 Giaquinta D, Boone R, Boskello M, et al. The perception of overactive bladder and its treatment in managed care. Manag Care Interface. 2005;18(Suppl B):20-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16201229].
1447 Gibb H, Wong G. How to choose: nurses’ judgements of the effectiveness of a range of currently marketed continence aids. J Clin Nurs. Mar. 1994;3(2):77-86. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8156138].
1448 Giberti C, Gallo F, Cortese P, et al. Transobturator tape for treatment of female stress urinary incontinence: objective and subjective results after a mean follow-up of two years. Urology. Apr. 2007;69(4):703-7. Not eligible exposure. [pmid: 17445655].
1449 Giberti C, Gallo F, Schenone M, et al. The bone-. anchor. sub-urethral sling for the treatment of iatrogenic male incontinence: subjective and objective assessment after 41 months of mean follow-up. World J Urol. Apr. 2008;26(2):173-8. Not eligible target population. [pmid: 17982750].
1450 Giberti C, Gallo F, Schenone M, et al. The bone anchor suburethral synthetic sling for iatrogenic male incontinence: critical evaluation at a mean 3-year followup. J Urol. May. 2009;181(5):2204-8. Not eligible target population. [pmid: 19296976].
1451 Giberti C, Rovida S. Transvaginal bone-anchored synthetic sling for the treatment of stress urinary incontinence: an outcomes analysis. Urology. Dec. 20. 2000;56(6):956-61. Not eligible exposure. [pmid: 11113740].
1452 Giberti C, Siracusano S, Gallo F, et al. Transvaginal bone-anchored sling procedure: 4 years of follow-up on more than 200 consecutive patients. Urology. Aug. 2008;72(2):313-7. discussion 7. Not eligible exposure. [pmid: 18554693].
1453 Gilbert R. Know your product: it’s vital for care. Nurs Times. Jul. 19–25. 2005;101(29):45. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16052944].
1454 Gilbert R, Glen M. Implementing an NHS continence service for nursing home residents. Prof Nurse. Nov. 2004;20(3):35-7. Not eligible target population. [pmid: 15552438].
1455 Gilbert SM, Wood DP, Dunn RL, et al. Measuring health-related quality of life outcomes in bladder cancer patients using the Bladder Cancer Index (BCI). Cancer. May. 1. 2007;109(9):1756-62. Not eligible target population. [pmid: 17366596].
1456 Gilja I. Tansvaginal needle suspension operation: the way we do it. Clinical and urodynamic study: long-term results. Eur Urol. Mar. 2000;37(3):325-30. Not eligible exposure. [pmid: 10720860].
1457 Gilja I, Puskar D, Mazuran B, et al. Comparative analysis of bladder neck suspension using Raz, Burch and transvaginal Burch procedures. A 3-year randomized prospective study. Eur Urol. 1998;33(3):298-302. Not eligible exposure. [pmid: 9555556].
1458 Gillam T. Desperate measures. Nurs Stand. Jun. 8–14. 2005;19(39):32-3. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15974544].
1459 Gilling P, Tu L, Nash S, et al. The Proact Adjustable Continence Therapy Device for the Treatment of Postprostatectomy Stress Urinary Incontinence. Paper presented at: 26th World Congress of Endourology (WCE 26), Shanghai International Convention Center (SICC). Shanghai (China). 30 Nov–3 Dec 2008. Not eligible target population.
1460 Gilling PJ, Bell DF, Wilson LC, et al. An adjustable continence therapy device for treating incontinence after prostatectomy: a minimum 2-year follow-up. BJU Int. Nov. 2008;102(10):1426-30. discussion 30–1. Not eligible target population. [pmid: 18564132].
1461 Gimbel H, Zobbe V, Andersen BJ, et al. Lower urinary tract symptoms after total and subtotal hysterectomy: results of a randomized controlled trial. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2005;16(4):257-62. Not eligible target population. [pmid: 16220584].
1462 Gimbel H, Zobbe V, Andersen BM, et al. Randomised controlled trial of total compared with subtotal hysterectomy with one-year follow up results. BJOG. Dec. 2003;110(12):1088-98. Not eligible target population. [pmid: 14664880].
1463 Gimbel H, Zobbe V, Andersen BM, et al. Total versus subtotal hysterectomy: an observational study with one-year follow-up. Aust N Z J Obstet Gynaecol. Feb. 2005;45(1):64-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15730368].
1464 Giramonti KM, Kogan BA, Halpern LF. The effects of anticholinergic drugs on attention span and short-term memory skills in children. Neurourol Urodyn. 2008;27(4):315-8. Not eligible target population. [pmid: 17828786].
1465 Girao MJ, Jarmy-Di Bella ZI, Sartori MG, et al. Doppler velocimetry parameters of periurethral vessels in postmenopausal incontinent women receiving estrogen replacement. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(4):241-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11569652].
1466 Giri SK, Drumm J, Saunders JA, et al. Day-case sling surgery for stress urinary incontinence: feasibility and safety. BJU Int. Apr. 2005;95(6):827-32. Not eligible exposure. [pmid: 15794792].
1467 Giuseppe PG, Pace G, Vicentini C. Sexual function in women with urinary incontinence treated by pelvic floor transvaginal electrical stimulation. J Sex Med. May. 2007;4(3):702-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17034409].
1468 Gladh G, Eldh M, Mattsson S. Quality of life in neurologically healthy children with urinary incontinence. Acta Paediatr. Dec. 2006;95(12):1648-52. Not eligible target population. [pmid: 17129976].
1469 Glavind K. Conservative treatment of stress incontinence with Geisha balls. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(4):223-4. discussion 4–5. Not eligible exposure. [pmid: 11569648].
1470 Glavind K, Kempf L. Colpectomy or Le Fort colpocleisis--a good option in selected elderly patients. Int Urogynecol J Pelvic Floor Dysfunct. Jan–Feb. 2005;16(1):48-51. discussion 15322743. Not eligible exposure. [pmid: 15322743].
1471 Glazener CM, Cooper K. Anterior vaginal repair for urinary incontinence in women. Cochrane Database Syst Rev. 2000;(3):CD001755. Not eligible exposure. [pmid: 10908510].
1472 Glazener CM, Cooper K. Anterior vaginal repair for urinary incontinence in women. Cochrane Database Syst Rev. 2001;(1):CD001755. Not eligible exposure. [pmid: 11279728].
1473 Glazener CM, Cooper K. Bladder neck needle suspension for urinary incontinence in women. Cochrane Database Syst Rev. 2002;(2):CD003636. Not eligible exposure. [pmid: 12076494].
1474 Glazener CM, Cooper K. Bladder neck needle suspension for urinary incontinence in women. Cochrane Database Syst Rev. 2004;(2):CD003636. Not eligible exposure. [pmid: 15106209].
1475 Glazener CM, Herbison GP, MacArthur C, et al. Randomised controlled trial of conservative management of postnatal urinary and faecal incontinence: six year follow up. BMJ. Feb. 12. 2005;330(7487):337. Not eligible target population. [pmid: 15615766].
1476 Glazener CM, Herbison GP, Wilson PD, et al. Conservative management of persistent postnatal urinary and faecal incontinence: randomised controlled trial. BMJ. Sep. 15. 2001;323(7313):593-6. Not eligible target population. [pmid: 11557703].
1477 Glazer HI, Romanzi L, Polaneczky M. Pelvic floor muscle surface electromyography. Reliability and clinical predictive validity. J Reprod Med. Sep. 1999;44(9):779-82. no associative hypothesis tested. [pmid: 10509301].
1478 Glenn J. Restorative Nursing Bladder Training program: recommending a strategy. Rehabil Nurs. Jan–Feb. 2003;28(1):15-22. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12567817].
1479 Gnanadesigan N, Saliba D, Roth CP, et al. The quality of care provided to vulnerable older community-based patients with urinary incontinence. Journal of the American Medical Directors Association. May–Jun. 2004;5(3):141-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15115573].
1480 Gnessin E, Livne PM, Baniel J, et al. Continence and quality of life assessment after artificial urinary sphincter implantation. Isr Med Assoc J. Oct. 2004;6(10):592-4. Not eligible exposure. [pmid: 15473584].
1481 Godfrey H. Older people, continence care and catheters: dilemmas and resolutions. Br J Nurs. May. 8–21. 2008;17(9):s4-11. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18567162].
1482 Goel MC, Roberts JG. Dynamic rectus abdominis tendon colposuspension for female stress urinary incontinence: a new procedure and its follow-up. Urol Int. 2003;71(1):45-50. Not eligible exposure. [pmid: 12845260].
1483 Goeman L, Salomon L, La De Taille A, et al. Long-term functional and oncological results after retroperitoneal laparoscopic prostatectomy according to a prospective evaluation of 550 patients. World J Urol. Aug. 2006;24(3):281-8. Not eligible target population. [pmid: 16508788].
1484 Goepel M, Hoffmann JA, Piro M, et al. Prevalence and physician awareness of symptoms of urinary bladder dysfunction. Eur Urol. Mar. 2002;41(3):234-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12180221].
1485 Gold MF. Restoring dignity. Provider. Apr. 1992;18(4):16-8. 20. 2. 4. Not eligible target population. [pmid: 10117297].
1486 Gold MF. Breaking through incontinence. Provider. Jul. 1995;21(7):70-2. 4. 6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10143792].
1487 Goldberg RP, Kwon C, Gandhi S, et al. Urinary incontinence after multiple gestation and delivery: impact on quality of life. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2005;16(5):334-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15700106].
1488 Goldberg RP, Sand PK. Extracorporeal electromagnetic stimulation for urinary incontinence and bladder disease. 2004;539 A:453-65. Review.
1489 Goldstein M, Hawthorne ME, Engeberg S, et al. Urinary incontinence. Why people do not seek help. J Gerontol Nurs. Apr. 1992;18(4):15-20. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 1569296].
1490 Goldstein SR, Neven P, Zhou L, et al. Raloxifene effect on frequency of surgery for pelvic floor relaxation. Obstet Gynecol. Jul. 2001;98(1):91-6. Not eligible outcomes. [pmid: 11430963].
1491 Gomes CM, Broderick GA, Sanchez-Ortiz RF, et al. Artificial urinary sphincter for post-prostatectomy incontinence: impact of prior collagen injection on cost and clinical outcome. J Urol. Jan. 2000;163(1):87-90. Not eligible target population. [pmid: 10604321].
1492 Gomes CM, Hisano M, Machado LR, et al. Urological manifestations of chronic schistosomal myeloradiculopathy. BJU Int. Oct. 2005;96(6):853-6. Not eligible target population. [pmid: 16153216].
1493 Gomha MA, Boone TB. Artificial urinary sphincter for post-prostatectomy incontinence in men who had prior radiotherapy: a risk and outcome analysis. J Urol. Feb. 2002;167(2 Pt 1):591-6. Not eligible target population. [pmid: 11792924].
1494 Gonzalez-Argente FX, Jain A, Nogueras JJ, et al. Prevalence and severity of urinary incontinence and pelvic genital prolapse in females with anal incontinence or rectal prolapse. Dis Colon Rectum. Jul. 2001;44(7):920-6. Not eligible target population. [pmid: 11496068].
1495 Goode PS, Burgio KL, Redden DT, et al. Population based study of incidence and predictors of urinary incontinence in black and white older adults. J Urol. Apr. 2008;179(4):1449-53. discussion 53–4. Not eligible target population. [pmid: 18295279].
1496 Gopal M, Sammel MD, Arya LA, et al. Association of change in estradiol to lower urinary tract symptoms during the menopausal transition. Obstet Gynecol. Nov. 2008;112(5):1045-52. Not eligible target population. [pmid: 18978104].
1497 Gordon D, Groutz A, Ascher-Landsberg J, et al. Double-blind, placebo-controlled study of magnesium hydroxide for treatment of sensory urgency and detrusor instability: preliminary results. Br J Obstet Gynaecol. Jun. 1998;105(6):667-9. Not eligible exposure. [pmid: 9647159].
1498 Gormley EA, Griffiths DJ, McCracken PN, et al. Polypharmacy and its effect on urinary incontinence in a geriatric population. Br J Urol. Mar. 1993;71(3):265-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8097424].
1499 Gosney M. General care of the older cancer patient. Clin Oncol (R Coll Radiol). Mar. 2009;21(2):86-91. Not eligible target population. [pmid: 19059769].
1500 Gotoh M, Mizutani K, Furukawa T, et al. Quality of micturition in male patients with orthotopic neobladder replacement. World J Urol. Dec. 2000;18(6):411-6. Not eligible target population. [pmid: 11204260].
1501 Gotoh M, Yoshikawa Y, Ohshima S. Pathophysiology and subjective symptoms in women with impaired bladder emptying. Int J Urol. Aug. 2006;13(8):1053-7. Not eligible target population. [pmid: 16903929].
1502 Govaert B, Pares D, Delgado-Aros S, et al. A prospective multicentre study to investigate percutaneous tibial nerve stimulation for the treatment of faecal incontinence. Colorectal Dis. Dec. 2010;12(12):1236-41. Not eligible target population. [pmid: 19674028].
1503 Govier FE, Litwiller S, Nitti V, et al. Percutaneous afferent neuromodulation for the refractory overactive bladder: results of a multicenter study. J Urol. Apr. 2001;165(4):1193-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11257669].
1504 Gozzi C, Schwentner C, Rehder P. Principles of Anatomy for Male Transobturator Tape (TOT) Suspension for the Treatment of Post-Prostatectomy Urinary Incontinence. Paper presented at: 2006 Annual Meeting of the American Urological Association (AUA 2006). Atlanta, Georgia (USA). 20–25 May 2006. Not eligible target population.
1505 Grady D, Brown JS, Vittinghoff E, et al. Postmenopausal hormones and incontinence: the Heart and Estrogen/Progestin Replacement Study. Obstet Gynecol. Jan. 2001;97(1):116-20. Not eligible exposure. [pmid: 11152919].
1506 Gralnek D, Wessells H, Cui H, et al. Differences in sexual function and quality of life after nerve sparing and nonnerve sparing radical retropubic prostatectomy. J Urol. Apr. 2000;163(4):1166-9. discussion 9–70. Not eligible target population. [pmid: 10737488].
1507 Granese R, Adile B. Tension-free cystocele repair: an analysis after a follow-up of 24 months. Minerva Ginecol. Aug. 2007;59(4):369-76. Not eligible exposure. [pmid: 17923828].
1508 Gray M. The importance of screening, assessing, and managing urinary incontinence in primary care. J Am Acad Nurse Pract. Mar. 2003;15(3):102-7. review. [pmid: 12696539].
1509 Gray M. Context for WOC practice: bowel & bladder management. J Wound Ostomy Continence Nurs. Nov–Dec. 2007;34(6):592-4. Not eligible target population. [pmid: 18030095].
1510 Gray M. Context for WOC practice: diabetic foot care, ostomy complications and pouch wear time, continence pad use, and challenges in research. Editorial J Wound Ostomy Continence Nurs. Sep–Oct. 2008;35(5):458-60. Not eligible target population. [pmid: 18794695].
1511 Grealish M, O’Dowd TC. General practitioners and women with urinary incontinence. Br J Gen Pract. Feb. 1998;48(427):975-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9624768].
1512 Green JP, Smoker I, Ho MT, et al. Urinary incontinence in subacute care--a retrospective analysis of clinical outcomes and costs. Med J Aust. Jun. 2. 2003;178(11):550-3. Not eligible target population. [pmid: 12765502].
1513 Green SA, Alon A, Ianus J, et al. Efficacy and safety of a neurokinin-1 receptor antagonist in postmenopausal women with overactive bladder with urge urinary incontinence. J Urol. Dec. 2006;176(6 Pt 1):2535-40. discussion 40. Not eligible exposure. [pmid: 17085151].
1514 Greenberger M, Steiner MS. The University of Tennessee. experience with the Indigo 830e laser device for the minimally invasive treatment of benign prostatic hyperplasia: interim analysis. World J Urol. 1998;16(6):386-91. Not eligible target population. [pmid: 9870285].
1515 Greendale GA, Petersen L, Zibecchi L, et al. Factors related to sexual function in postmenopausal women with a history of breast cancer. Menopause. Summer. 2001;8(2):111-9. Not eligible target population. [pmid: 11256871].
1516 Greenfield SP, Fera M. The use of intravesical oxybutynin chloride in children with neurogenic bladder. J Urol. Aug. 1991;146(2 ( Pt 2)):532-4. Not eligible target population. [pmid: 1861294].
1517 Grein U, Meyer WW. Local recurrent cancer after radical prostatectomy and incontinence. Is the artificial urinary sphincter a useful therapeutic option?. Urol Int. 2001;66(1):9-12. Not eligible target population. [pmid: 11150943].
1518 Grieve T. Continence promotion among children with severe disabilities. Nurs Times. Oct. 14–20. 1998;94(41):58-9. Not eligible target population. [pmid: 9832873].
1519 Griffiths D, Harrison G, Moore K, et al. Long-term changes in urodynamic studies of voiding in the elderly. Urol Res. 1994;22(4):235-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7871636].
1520 Griffiths DJ, McCracken PN, Harrison GM, et al. Urge incontinence in elderly people: factors predicting the severity of urine loss before and after pharmacological treatment. Neurourol Urodyn. 1996;15(1):53-7. Case series. [pmid: 8696356].
1521 Grignaffini A, Bazzani F, Bertoli P, et al. Intravesicular prostaglandin E2 for the prophylaxis of urinary retention after colpohysterectomy. J Int Med Res. Mar–Apr. 1998;26(2):87-92. Not eligible target population. [pmid: 9602987].
1522 Grimby A, Milsom I, Molander U, et al. The influence of urinary incontinence on the quality of life of elderly women. Age Ageing. Mar. 1993;22(2):82-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8470564].
1523 Grimby A, Rosenhall U. Health-related quality of life and dizziness in old age. Gerontology. 1995;41(5):286-98. Not eligible target population. [pmid: 8537013].
1524 Grimby A, Svanborg A. Morbidity and health-related quality of life among ambulant elderly citizens. Aging (Milano). Oct. 1997;9(5):356-64. Not eligible target population. [pmid: 9458996].
1525 Grocela JA, Kanji A, Ternullo J. Prediction of Medicare drug formulary drugs for treatment of overactive bladder. J Urol. Jul. 2006;176(1):252-5. discussion 5–6. Not eligible outcomes. [pmid: 16753413].
1526 Grodstein F, Lifford K, Resnick NM, et al. Postmenopausal hormone therapy and risk of developing urinary incontinence. Obstet Gynecol. Feb. 2004;103(2):254-60. Not eligible target population. [pmid: 14754692].
1527 Groen J, van der Horst A, Blok B. Urodynamic Effects of Adjustable Continence Therapy for Men with Stress Urinary Incontinence after Radical Prostatectomy. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep –3 Oct 2009. Not eligible target population.
1528 Grosse J, Kramer G, Stohrer M. Success of repeat detrusor injections of botulinum a toxin in patients with severe neurogenic detrusor overactivity and incontinence. Eur Urol. May. 2005;47(5):653-9. Not eligible target population. [pmid: 15826758].
1529 Grossklaus DJ, Franke JJ. Treatment of elderly women with urge incontinence in middle tennessee: a single institution practice-based study. Tenn Med. Dec. 2000;93(12):457-60. Case-series. [pmid: 11117074].
1530 Groutz A, Blaivas JG, Chaikin DC, et al. Noninvasive outcome measures of urinary incontinence and lower urinary tract symptoms: a multicenter study of micturition diary and pad tests. J Urol. Sep. 2000;164(3 Pt 1):698-701. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10953128].
1531 Guerette NL, Peterson TV, Aguirre OA, et al. Anterior repair with or without collagen matrix reinforcement: a randomized controlled trial. Obstet Gynecol. Jul. 2009;114(1):59-65. Not eligible exposure. [pmid: 19546759].
1532 Guerrero K, Emery S, Owen L, et al. Intravesical oxybutynin: practicalities of clinical use. J Obstet Gynaecol. Feb. 2006;26(2):141-3. Not eligible exposure. [pmid: 16483973].
1533 Guerrero K, Watkins A, Emery S, et al. A randomised controlled trial comparing two autologous fascial sling techniques for the treatment of stress urinary incontinence in women: short, medium and long-term follow-up. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2007;18(11):1263-70. Not eligible exposure. [pmid: 17347792].
1534 Guimaraes M, Oliveira R, Pinto R, et al. Intermediate-term results, up to 4 years, of a bone-anchored male perineal sling for treating male stress urinary incontinence after prostate surgery. BJU Int. Feb. 2009;103(4):500-4. Not eligible target population. [pmid: 18782301].
1535 Gundian JC, Barrett DM, Parulkar BG. Mayo Clinic experience with the AS800 artificial urinary sphincter for urinary incontinence after transurethral resection of prostate or open prostatectomy. Urology. Apr. 1993;41(4):318-21. Not eligible target population. [pmid: 8470315].
1536 Gunningberg L. Risk, prevalence and prevention of pressure ulcers in three Swedish healthcare settings. J Wound Care. Jul. 2004;13(7):286-90. Not eligible target population. [pmid: 15977770].
1537 Gupta G, Aronow WS. Hormone replacement therapy. An analysis of efficacy based on evidence. Geriatrics. Aug. 2002;57(8):18-20. 3. 4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12201226].
1538 Gupta NP, Doddamani D, Aron M, et al. Vapor resection: a good alternative to standard loop resection in the management of prostates >40 cc. J Endourol. Dec. 2002;16(10):767-71. Not eligible target population. [pmid: 12542882].
1539 Guys JM, Haddad M, Planche D, et al. Sacral neuromodulation for neurogenic bladder dysfunction in children. J Urol. Oct. 2004;172(4 Pt 2):1673-6. Not eligible target population. [pmid: 15371787].
1540 Haab F, Trockman BA, Zimmern PE, et al. Quality of life and continence assessment of the artificial urinary sphincter in men with minimum 3.5 years of followup. J Urol. Aug. 1997;158(2):435-9. Not eligible target population. [pmid: 9224318].
1541 Haab F, Trockman BA, Zimmern PE, et al. Results of pubovaginal sling for the treatment of intrinsic sphincteric deficiency determined by questionnaire analysis. J Urol. Nov. 1997;158(5):1738-41. Not eligible exposure. [pmid: 9334590].
1542 Haab F, Zimmern PE, Leach GE. Urinary stress incontinence due to intrinsic sphincteric deficiency: experience with fat and collagen periurethral injections. The Journal of urology. 1997:1283-6. Not eligible exposure. [pmid: 9120921].
1543 Hadley HR, Pineda EB. The urethral sling and stress urinary incontinence. West J Med. Sep. 1998;169(3):167-8. Not eligible exposure. [pmid: 9771157].
1544 Hadorn DC, McCormick K, Diokno A. An annotated algorithm approach to clinical guideline development. JAMA. Jun. 24. 1992;267(24):3311-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 1597913].
1545 Haferkamp A, Staehler G, Gerner HJ, et al. Dosage escalation of intravesical oxybutynin in the treatment of neurogenic bladder patients. Spinal Cord. Apr. 2000;38(4):250-4. Not eligible exposure. [pmid: 10822396].
1546 Hafez AT, Elsherbiny MT, Ghoneim MA. Complete repair of bladder exstrophy: preliminary experience with neonates and children with failed initial closure. J Urol. Jun. 2001;165(6 Pt 2):2428-30. Not eligible target population. [pmid: 11371991].
1547 Hagen S, Glazener C, Cook J, et al. Further properties of the pelvic organ prolapse symptom score: Minimally important change and test-retest reliability. Paper presented at: Neurourology and Urodynamics, 2010; Joint Meeting of the International Continence Society and the International Urogynecological Association. Toronto, Canada. 23–27 August 2010. Not eligible target population.
1548 Hagglof B, Andren O, Bergstrom E, et al. Self-esteem before and after treatment in children with nocturnal enuresis and urinary incontinence. Scand J Urol Nephrol Suppl. 1997;183:79-82. Not eligible target population. [pmid: 9165615].
1549 Hagglund D, Ahlstrom G. The meaning of women’s experience of living with long-term urinary incontinence is powerlessness. J Clin Nurs. Oct. 2007;16(10):1946-54. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17880483].
1550 Hagglund D, Olsson H, Leppert J. Urinary incontinence: an unexpected large problem among young females. Results from a population-based study. Fam Pract. Oct. 1999;16(5):506-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10533948].
1551 Hagglund D, Wadensten B. Fear of humiliation inhibits women’s care-seeking behaviour for long-term urinary incontinence. Scand J Caring Sci. Sep. 2007;21(3):305-12. Not eligible target population. [pmid: 17727542].
1552 Hagglund D, Walker-Engstrom ML, Larsson G, et al. Quality of life and seeking help in women with urinary incontinence. Acta Obstet Gynecol Scand. Nov. 2001;80(11):1051-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11703207].
1553 Hagglund D, Walker-Engstrom ML, Larsson G, et al. Reasons why women with long-term urinary incontinence do not seek professional help: a cross-sectional population-based cohort study. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2003;14(5):296-304. discussion 14618304. Not elgible target population. [pmid: 14618304].
1554 Hagglund D, Walker-Engstrom ML, Larsson G, et al. Changes in urinary incontinence and quality of life after four years. A population-based study of women aged 22–50 years. Scand J Prim Health Care. Jun. 2004;22(2):112-7. Not eligible exposure. [pmid: 15255492].
1555 Hagstroem S, Mahler B, Madsen B, et al. Transcutaneous electrical nerve stimulation for refractory daytime urinary urge incontinence. J Urol. Oct. 2009;182(4 Suppl):2072-8. Not eligible target population. [pmid: 19695629].
1556 Hagstroem S, Rittig N, Kamperis K, et al. Treatment outcome of day-time urinary incontinence in children. Scand J Urol Nephrol. 2008;42(6):528-33. Not eligible target population. [pmid: 18609267].
1557 Hahn I, Milsom I, Fall M, et al. Long-term results of pelvic floor training in female stress urinary incontinence. Br J Urol. Oct. 1993;72(4):421-7. Level of evidence. [pmid: 8261297].
1558 Hahn RG, Fagerstrom T, Tammela TL, et al. Blood loss and postoperative complications associated with transurethral resection of the prostate after pretreatment with dutasteride. BJU Int. Mar. 2007;99(3):587-94. Not eligible target population. [pmid: 17407516].
1559 Hajebrahimi S, Azaripour A, Sadeghi-Bazargani H. Tolterodine immediate release improves sexual function in women with overactive bladder. J Sex Med. Dec. 2008;5(12):2880-5. Level of evidence. [pmid: 18785896].
1560 Hajebrahimi S, Corcos J, Lemieux MC. International consultation on incontinence questionnaire short form: comparison of physician versus patient completion and immediate and delayed self-administration. Urology. Jun. 2004;63(6):1076-8. Not eligible exposure. [pmid: 15183953].
1561 Hall JA, Nelson MA, Meyer JW, et al. Costs and resources associated with the treatment of overactive bladder using retrospective medical care claims data. Manag Care Interface. Aug. 2001;14(8):69-75. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11517841].
1562 Hall JD, Boyd JC, Lippert MC, et al. Why patients choose prostatectomy or brachytherapy for localized prostate cancer: results of a descriptive survey. Urology. Feb. 2003;61(2):402-7. Not eligible target population. [pmid: 12597956].
1563 Haltbakk J, Hanestad BR, Hunskaar S. Relevance and variability of the severity of incontinence, and increased daytime and night-time voiding frequency, associated with quality of life in men with lower urinary tract symptoms. BJU Int. Jul. 2005;96(1):83-7. Not eligible target population. [pmid: 15963126].
1564 Haltbakk J, Hanestad BR, Hunskaar S. How important are men’s lower urinary tract symptoms (LUTS) and their impact on the quality of life (QOL)?. Qual Life Res. Sep. 2005;14(7):1733-41. Not eligible target population. [pmid: 16119184].
1565 Halverson AL, Hull TL, Paraiso MF, et al. Outcome of sphincteroplasty combined with surgery for urinary incontinence and pelvic organ prolapse. Dis Colon Rectum. Oct. 2001;44(10):1421-6. Not eligible target population. [pmid: 11598469].
1566 Hamilton AS, Stanford JL, Gilliland FD, et al. Health outcomes after external-beam radiation therapy for clinically localized prostate cancer: results from the Prostate Cancer Outcomes Study. J Clin Oncol. May. 1. 2001;19(9):2517-26. Not eligible target population. [pmid: 11331331].
1567 Hampel C, Wienhold D, Benken N, et al. Prevalence and natural history of female incontinence. Eur Urol. 1997;32(Suppl 2):3-12. Not eligible target population. [pmid: 9248806].
1568 Hampel C, Wienhold D, Benken N, et al. Definition of overactive bladder and epidemiology of urinary incontinence. Urology. Dec. 1997;50(6A Suppl):4-14. discussion 5–7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9426746].
1569 Hamvas A, Nagy F, Tanko A. The role of Melipramine in the treatment of bladder instability. Ther Hung. 1993;41(4):150-2. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8029784].
1570 Han E, Black LK, Lavelle JP. Incontinence related to management of benign prostatic hypertrophy. Am J Geriatr Pharmacother. Dec. 2007;5(4):324-34. Not eligible target population. [pmid: 18179990].
1571 Hancock R, Bender P, Dayhoff N, et al. Factors associated with nursing interventions to reduce incontinence in hospitalized older adults. Urol Nurs. Sep. 1996;16(3):79-85. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9295797].
1572 Handa VL, Barber MD, Young SB, et al. Paper versus web-based administration of the Pelvic Floor Distress Inventory 20 and Pelvic Floor Impact Questionnaire 7. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2008;19(10):1331-5. Not eligible outcomes. [pmid: 18488134].
1573 Handa VL, Zyczynski HM, Burgio KL, et al. The impact of fecal and urinary incontinence on quality of life 6 months after childbirth. Am J Obstet Gynecol. Dec. 2007;197(6):636 e1-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18060960].
1574 Hannah ME, Hannah WJ, Hodnett ED, et al. Outcomes at 3 months after planned cesarean vs planned vaginal delivery for breech presentation at term: the international randomized Term Breech Trial. JAMA. Apr. 10. 2002;287(14):1822-31. Not eligible target population. [pmid: 11939868].
1575 Hannah ME, Whyte H, Hannah WJ, et al. Maternal outcomes at 2 years after planned cesarean section versus planned vaginal birth for breech presentation at term: the international randomized Term Breech Trial. Am J Obstet Gynecol. Sep. 2004;191(3):917-27. Not eligible target population. [pmid: 15467565].
1576 Hannappel J, Krieger S. Subjective and clinical results after transurethral resection and suprapubic prostatectomy in benign prostatic hypertrophy. Eur Urol. 1991;20(4):272-6. Not eligible target population. [pmid: 1726084].
1577 Hannestad YS, Rortveit G, Hunskaar S. Help-seeking and associated factors in female urinary incontinence. The Norwegian EPINCONT Study. Epidemiology of Incontinence in the County of Nord-Trondelag. Scand J Prim Health Care. Jun. 2002;20(2):102-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12184708].
1578 Hara I, Kawabata G, Miyake H, et al. Comparison of quality of life following laparoscopic and open prostatectomy for prostate cancer. J Urol. Jun. 2003;169(6):2045-8. Not eligible target population. [pmid: 12771715].
1579 Harano M, Eto M, Nakamura M, et al. A pilot study of the assessment of the quality of life, functional results, and complications in patients with an ileal neobladder for invasive bladder cancer. Int J Urol. Feb. 2007;14(2):112-7. Not eligible target population. [pmid: 17302566].
1580 Harari D, Igbedioh C. Restoring continence in frail older people living in the community: what factors influence successful treatment outcomes?. Age Ageing. Mar. 2009;38(2):228-33. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 19106253].
1581 Harari D, Martin FC, Buttery A, et al. The older persons’ assessment and liaison team ‘OPAL’: evaluation of comprehensive geriatric assessment in acute medical inpatients. Age Ageing. Nov. 2007;36(6):670-5. Not eligible target population. [pmid: 17656421].
1582 Harke JM, Richgels K. Barriers to implementing a continence program in nursing homes. Clin Nurs Res. May. 1992;1(2):158-68. Not eligible target population. [pmid: 1301859].
1583 Harmanli OH, Dandolu V, Chatwani AJ, et al. Total colpocleisis for severe pelvic organ prolapse. J Reprod Med. Sep. 2003;48(9):703-6. Not eligible target population. [pmid: 14562635].
1584 Harmanli OH, Okafor O, Ayaz R, et al. Lidocaine jelly and plain aqueous gel for urethral straight catheterization and the Q-tip test: a randomized controlled trial. Obstet Gynecol. Sep. 2009;114(3):547-50. Not eligible exposure. [pmid: 19701033].
1585 Harrington C, Zimmerman D, Karon SL, et al. Nursing home staffing and its relationship to deficiencies. J Gerontol B Psychol Sci Soc Sci. Sep. 2000;55(5):S278-87. Not eligible target population. [pmid: 10985299].
1586 Harris PF. Medical issues and hormone replacement therapy. Curr Womens Health Rep. Oct. 2002;2(5):373-81. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12215310].
1587 Harris SS, Link CL, Tennstedt SL, et al. Care seeking and treatment for urinary incontinence in a diverse population. J Urol. Feb. 2007;177(2):680-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17222656].
1588 Hart KJ, Palmer MH, Fitzgerald S. Perceived causes of urinary incontinence and reporting: a study with working women. Clin Nurs Res. Feb. 1999;8(1):84-92. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10358493].
1589 Hart SR, Moore RD, Miklos JR, et al. Incidence of concomitant surgery for pelvic organ prolapse in patients surgically treated for stress urinary incontinence. Journal of Reproductive Medicine. Jul. 2006;51(7):521-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16913541].
1590 Hartnett NM, Saver BG. Is extended-release oxybutynin (Ditropan XL) or tolterodine (Detrol) more effective in the treatment of an overactive bladder?. J Fam Pract. Jul. 2001;50(7):571. Comment. [pmid: 11485700].
1591 Hashim H. Solifenacin in overactive bladder: a viewpoint by Hashim Hashim. Drugs Aging. 2005;22(12):1070. Comment. [pmid: 16363889].
1592 Hashim H, Avery K, Mourad MS, et al. The Arabic ICIQ-UI SF: an alternative language version of the English ICIQ-UI SF. Neurourol Urodyn. 2006;25(3):277-82. no associated hypothesis tested. [pmid: 16532458].
1593 Hashimoto K, Ohnishi N, Esa A, et al. Clinical efficacy of oxybutynin on sensory urgency as compared with that on motor urgency. Urol Int. 1999;62(1):12-6. Not eligible case series. [pmid: 10436424].
1594 Haslam J. The prevalence of stress urinary incontinence in women. Nurs Times. May. 18. 2004;100(20):71-3. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15176284].
1595 Haslam J. Urinary incontinence: why women do not ask for help. Nurs Times. Nov. 22–28. 2005;101(47):47-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16329276].
1596 Hassink EA, Rieu PN, Severijnen RS, et al. Are adults content or continent after repair for high anal atresia? A long-term follow-up study in patients 18 years of age and older. Ann Surg. Aug. 1993;218(2):196-200. Not eligible target population. [pmid: 8343000].
1597 Hassouna ME, Ghoniem GM. Long-term outcome and quality of life after modified pubovaginal sling for intrinsic sphincteric deficiency. Urology. Feb. 1999;53(2):287-91. Not eligible exposure. [pmid: 9933041].
1598 Hatem M, Fraser W, Lepire E. Postpartum urinary and anal incontinence: a population-based study of quality of life of primiparous women in Quebec. J Obstet Gynaecol Can. Jul. 2005;27(7):682-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16100623].
1599 Haugen V, Moore A. “I will manage”: promoting continence through community education. J Wound Ostomy Continence Nurs. Nov. 1995;22(6):291-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8704840].
1600 Hautmann RE, Sauter TW, Wenderoth UK. Radical retropubic prostatectomy: morbidity and urinary continence in 418 consecutive cases. Urology. Feb. 1994;43(2 Suppl):47-51. Not eligible target population. [pmid: 8116133].
1601 Hawkins E, Taylor D, Hughes-Nurse J. Long term follow up of the cruciate fascial sling for women with genuine stress incontinence. BJOG. Mar. 2002;109(3):327-38. Not eligible exposure. [pmid: 11950189].
1602 Hayder D, Schnepp W. Urinary incontinence - the family caregivers’ perspective. Z Gerontol Geriatr. Aug. 2008;41(4):261-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18677628].
1603 Hayn MA, Greco SJ, Capuano K, et al. Compliance with pelvic floor exercise program: maintaining bladder symptom relief. Urol Nurs. Apr. 2000;20(2):129-31. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11998123].
1604 Hay-Smith J, Morkved S, Fairbrother KA, et al. Pelvic floor muscle training for prevention and treatment of urinary and faecal incontinence in antenatal and postnatal women. Cochrane Database Syst Rev. 2008;(4):CD007471. Not eligible target population. [pmid: 18843750].
1605 Haywood KL, Garratt AM, Lall R, et al. EuroQol EQ-5D and condition-specific measures of health outcome in women with urinary incontinence: reliability, validity and responsiveness. Qual Life Res. Apr. 2008;17(3):475-83. Not eligible outcomes. [pmid: 18274881].
1606 Heathcote PS, Mactaggart PN, Boston RJ, et al. Health-related quality of life in Australian men remaining disease-free after radical prostatectomy. Med J Aust. May. 18. 1998;168(10):483-6. Not eligible target population. [pmid: 9631671].
1607 Hegde SS, Eglen RM. Muscarinic receptor subtypes modulating smooth muscle contractility in the urinary bladder. Life Sci. 1999;64(6–7):419-28. Not eligible target population. [pmid: 10069505].
1608 Heidrich SM, Wells TJ. Effects of urinary incontinence: psychological well-being and distress in older community-dwelling women. J Gerontol Nurs. May. 2004;30(5):47-54. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15152744].
1609 Heit M, Blackwell L, Kelly S. Measuring the utility of incontinence care seeking. Int Urogynecol J Pelvic Floor Dysfunct. Jan. 2008;19(1):143-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17579800].
1610 Heit M, Blackwell L, Kelly S. Measuring barriers to incontinence care seeking. Neurourol Urodyn. 2008;27(3):174-8. Not eligible exposure. [pmid: 17621356].
1611 Heit M, Blackwell L, Ouseph R. Comorbidities affect the impact of urinary incontinence as measured by disease-specific quality of life instruments. Int Urogynecol J Pelvic Floor Dysfunct. Jan–Feb. 2005;16(1):6-11. discussion 15292980. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15292980].
1612 Heit M, Blackwell L, Thomas S, et al. Prevalence and severity of urinary incontinence in kidney transplant recipients. Obstet Gynecol. Feb. 2004;103(2):352-8. Not eligible target population. [pmid: 14754708].
1613 Heit M, Brubaker L. Clinical correlates in patients not completing a voiding diary. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(5):256-9. no associative hypothesis tested. [pmid: 9127182].
1614 Helgason AR, Adolfsson J, Dickman P, et al. Waning sexual function--the most important disease-specific distress for patients with prostate cancer. Br J Cancer. Jun. 1996;73(11):1417-21. Not eligible target population. [pmid: 8645589].
1615 Heliovaara-Peippo S, Halmesmaki K, Hurskainen R, et al. The effect of hysterectomy or levonorgestrel-releasing intrauterine system on lower urinary tract symptoms: a 10-year follow-up study of a randomised trial. BJOG. Apr. 2010;117(5):602-9. Not eligible exposure. [pmid: 20156209].
1616 Hellstrom A, Hanson E, Hansson S, et al. Micturition habits and incontinence at age 17--reinvestigation of a cohort studied at age 7. Br J Urol. Aug. 1995;76(2):231-4. Not eligible target population. [pmid: 7663917].
1617 Helstrom L, Nilsson B. Impact of vaginal surgery on sexuality and quality of life in women with urinary incontinence or genital descensus. Acta Obstet Gynecol Scand. Jan. 2005;84(1):79-84. Not eligible exposure. [pmid: 15603572].
1618 Henalla SM, Hall V, Duckett JR, et al. A multicentre evaluation of a new surgical technique for urethral bulking in the treatment of genuine stress incontinence. BJOG. Aug. 2000;107(8):1035-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10955438].
1619 Henderson JS, Kashka MS. Development and testing of the Urinary Incontinence Scales. Urol Nurs. Jun. 1999;19(2):109-19. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10633762].
1620 Hendrix SL, Cochrane BB, Nygaard IE, et al. Effects of estrogen with and without progestin on urinary incontinence. JAMA. Feb. 23. 2005;293(8):935-48. Not eligible exposure. [pmid: 15728164].
1621 Herbison P, Hay-Smith J, Paterson H, et al. Research priorities in urinary incontinence: results from citizens’ juries. BJOG. Apr. 2009;116(5):713-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 19298439].
1622 Hernandez RD, Hurwitz RS, Foote JE, et al. Nonsurgical management of threatened upper urinary tracts and incontinence in children with myelomeningocele. J Urol. Nov. 1994;152(5 Pt 1):1582-5. Not eligible target population. [pmid: 7933209].
1623 Herr HW. Quality of life of incontinent men after radical prostatectomy. J Urol. Mar. 1994;151(3):652-4. Not eligible target population. [pmid: 8308974].
1624 Herron-Marx S, Williams A, Hicks C. A Q methodology study of women’s experience of enduring postnatal perineal and pelvic floor morbidity. Midwifery. Sep. 2007;23(3):322-34. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17126457].
1625 Herschorn S, Jones JS, Oelke M, et al. Efficacy and tolerability of fesoterodine in men with overactive bladder: a pooled analysis of 2 phase III studies. Urology. May. 2010;75(5):1149-55. not eligible target population. [pmid: 19914702].
1626 Herschorn S, Liu M. Artificial Urinary Sphincter and In-Vance Male Sling in the Treatment of Post-Prostatectomy Incontinence: A Comparison Study. Paper presented at: 21st Annual Congress of the European Association of Urology (EAU 2006), Palais des Congres. Paris (France). 5–8 Apr 2006. Not eligible target population.
1627 Herwig R, Bruns F, Strasser H, et al. Late urologic effects after adjuvant irradiation in stage I endometrial carcinoma. Urology. Feb. 2004;63(2):354-8. Not eligible target population. [pmid: 14972490].
1628 Hetzer FH, Hahnloser D, Clavien PA, et al. Quality of life and morbidity after permanent sacral nerve stimulation for fecal incontinence. Arch Surg. Jan. 2007;142(1):8-13. Not eligible target population. [pmid: 17224495].
1629 Hicken BL, Putzke JD, Richards JS. Bladder management and quality of life after spinal cord injury. Am J Phys Med Rehabil. Dec. 2001;80(12):916-22. Not eligible target population. [pmid: 11821674].
1630 Higashi T, Hays RD, Brown JA, et al. Do proxies reflect patients’ health concerns about urinary incontinence and gait problems?. Health Qual Life Outcomes. 2005;3:75. not eligible target population. [pmid: 16305748].
1631 Higgs P, Goh J, Krause H, et al. Abdominal sacral colpopexy: an independent prospective long-term follow-up study. Aust N Z J Obstet Gynaecol. Oct. 2005;45(5):430-4. Not eligible exposure. [pmid: 16171482].
1632 Hilton EL, Henderson LJ. Lived female experience of chronic bladder cancer: a phenomenologic case study. Urol Nurs. Oct. 2003;23(5):349-54. Not eligible target population. [pmid: 14621357].
1633 Hiltunen R, Nieminen K, Takala T, et al. Low-weight polypropylene mesh for anterior vaginal wall prolapse: a randomized controlled trial. Obstet Gynecol. Aug. 2007;110(2 Pt 2):455-62. Not eligible exposure. [pmid: 17666627].
1634 Hines SH, Sampselle CM, Ronis DL, et al. Women’s self-care agency to manage urinary incontinence: the impact of nursing agency and body experience. ANS Adv Nurs Sci. Apr–Jun. 2007;30(2):175-88. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17510574].
1635 Hinze J, Junkin J. The latest in treatments for incontinence in women. Nebr Nurse. Jun–Aug. 2006;39(2):22-6. quiz 7–8. Comment. [pmid: 16789399].
1636 Hirai K, Ishiko O, Sumi T, et al. Indifference and resignation of Japanese women toward urinary incontinence. Int J Gynaecol Obstet. Oct. 2001;75(1):89-91. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11597629].
1637 Hirata H, Matsuyama H, Yamakawa G, et al. Does surgical repair of pelvic prolapse improve patients’ quality of life?. Eur Urol. Feb. 2004;45(2):213-8. Not eligible exposure. [pmid: 14734009].
1638 Hjalmas K, Hellstrom AL, Mogren K, et al. The overactive bladder in children: a potential future indication for tolterodine. BJU Int. Apr. 2001;87(6):569-74. Not eligible target population. [pmid: 11298060].
1639 Ho C. Transdermally-delivered oxybutynin (Oxytrol(R) for overactive bladder. Issues Emerg Health Technol. Oct. 2001;(24):1-4. Comment. [pmid: 11776281].
1640 Ho YH, Muller R, Veitch C, et al. Faecal incontinence: an unrecognised epidemic in rural North Queensland? Results of a hospital-based outpatient study. Aust J Rural Health. Feb. 2005;13(1):28-34. Not eligible target population. [pmid: 15720312].
1641 Hocking J. Continence problems: how to tackle reticence of patients. Nurs Times. Jan. 6–12. 1999;95(1):56-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10067578].
1642 Hodgins D. Urinary incontinence: how technology can help. Med Device Technol. Dec. 2005;16(10):16-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16419919].
1643 Hoebeke P, De Caestecker K, Vande Walle J, et al. The effect of botulinum-A toxin in incontinent children with therapy resistant overactive detrusor. J Urol. Jul. 2006;176(1):328-30. discussion 30–1. Not eligible target population. [pmid: 16753434].
1644 Hoebeke P, De Kuyper P, Goeminne H, et al. Bladder neck closure for treating pediatric incontinence. Eur Urol. Oct. 2000;38(4):453-6. Not eligible target population. [pmid: 11025385].
1645 Hoffman JR, Wilkes MS, Day FC, et al. The roulette wheel: an aid to informed decision making. PLoS Med. Jun. 2006;3(6):e137. Comment. [pmid: 16752950].
1646 Hofner K, Burkart M, Jacob G, et al. Safety and efficacy of tolterodine extended release in men with overactive bladder symptoms and presumed non-obstructive benign prostatic hyperplasia. World J Urol. Dec. 2007;25(6):627-33. Not eligible target population. [pmid: 17906864].
1647 Hohenfellner M, Nunes L, Schmidt RA, et al. Interstitial cystitis: increased sympathetic innervation and related neuropeptide synthesis. J Urol. Mar. 1992;147(3):587-91. Not eligible target population. [pmid: 1538434].
1648 Hol M, van Bolhuis C, Vierhout ME. Vaginal ultrasound studies of bladder neck mobility. Br J Obstet Gynaecol. Jan. 1995;102(1):47-53. Not eligible exposure. [pmid: 7833310].
1649 Holland AJ, King PA, Chauvel PJ, et al. Intravesical therapy for the treatment of neurogenic bladder in children. Aust N Z J Surg. Oct. 1997;67(10):731-3. Not eligible target population. [pmid: 9322726].
1650 Hollenbeck BK, Lipp ER, Hayward RA, et al. Concurrent assessment of obstructive/irritative urinary symptoms and incontinence after radical prostatectomy. Urology. Mar. 2002;59(3):389-93. Not eligible target population. [pmid: 11880076].
1651 Holmgren C, Hellberg D, Lanner L, et al. Quality of life after tension-free vaginal tape surgery for female stress incontinence. Scand J Urol Nephrol. 2006;40(2):131-7. Not eligible exposure. [pmid: 16608811].
1652 Holmgren C, Nilsson S, Lanner L, et al. Long-term results with tension-free vaginal tape on mixed and stress urinary incontinence. Obstet Gynecol. Jul. 2005;106(1):38-43. Not eligible exposure. [pmid: 15994615].
1653 Holmgren C, Nilsson S, Lanner L, et al. Frequency of de novo urgency in 463 women who had undergone the tension-free vaginal tape (TVT) procedure for genuine stress urinary incontinence--a long-term follow-up. Eur J Obstet Gynecol Reprod Biol. May. 2007;132(1):121-5. Not eligible exposure. [pmid: 16815624].
1654 Homma Y, Kawabe K, Hayashi K. Urologic morbidity and its influence on global satisfaction with treatment outcome after radical prostatectomy for prostate cancer. Int J Urol. Nov. 1998;5(6):556-61. Not eligible target population. [pmid: 9855124].
1655 Homma Y, Yamaguchi O, Hayashi K. An epidemiological survey of overactive bladder symptoms in Japan. BJU Int. Dec. 2005;96(9):1314-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16287452].
1656 Homma Y, Yoshida M, Seki N, et al. Symptom assessment tool for overactive bladder syndrome--overactive bladder symptom score. Urology. Aug. 2006;68(2):318-23. Not eligible outcomes. [pmid: 16904444].
1657 Hooper P, Tincello DG, Richmond DH. The use of salivary stimulant pastilles to improve compliance in women taking oxybutynin hydrochloride for detrusor instability: a pilot study. Br J Urol. Sep. 1997;80(3):414-6. Not eligible exposure. [pmid: 9313659].
1658 Horrocks S, Somerset M, Stoddart H, et al. What prevents older people from seeking treatment for urinary incontinence? A qualitative exploration of barriers to the use of community continence services. Fam Pract. Dec. 2004;21(6):689-96. Not eligible exposure. [pmid: 15528285].
1659 Horstmann M, Schaefer T, Aguilar Y, et al. Neurogenic bladder treatment by doubling the recommended antimuscarinic dosage. Neurourol Urodyn. 2006;25(5):441-5. Not eligible population. [pmid: 16847942].
1660 Hoscan MB, Dilmen C, Perk H, et al. Extracorporeal magnetic innervation for the treatment of stress urinary incontinence: results of two-year follow-up. Urol Int. 2008;81(2):167-72. Level of evidence. [pmid: 18758214].
1661 Hosseini SV, Sharifi K, Ahmadfard A, et al. Role of internal sphincterotomy in the treatment of hemorrhoids: a randomized clinical trial. Arch Iran Med. Oct. 2007;10(4):504-8. Not eligible target population. [pmid: 17903056].
1662 Ho-Yin PL, Man-Wah P, Shing-Kai Y. Effects of aging on generic SF-36 quality of life measurements in Hong Kong Chinese women with urinary incontinence. Acta Obstet Gynecol Scand. Mar. 2003;82(3):275-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12694125].
1663 Hsieh CH, Hsu CS, Su TH, et al. Risk factors for urinary incontinence in Taiwanese women aged 60 or over. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2007;18(11):1325-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17912573].
1664 Hsieh CH, Kuo TC, Hsu CS, et al. Nocturia among women aged 60 or older in Taiwan. Aust N Z J Obstet Gynaecol. Jun. 2008;48(3):312-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18532964].
1665 Hsieh CH, Su TH, Chang ST. Prevalence of and attitude toward urinary incontinence in Taiwanese women. Int J Gynaecol Obstet. Feb. 2005;88(2):152-3. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15694096].
1666 Hsieh CH, Su TH, Chang ST, et al. Prevalence of and attitude toward urinary incontinence in postmenopausal women. Int J Gynaecol Obstet. Feb. 2008;100(2):171-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17977542].
1667 Hsieh CL, Sheu CF, Hsueh IP, et al. Trunk control as an early predictor of comprehensive activities of daily living function in stroke patients. Stroke. Nov. 2002;33(11):2626-30. Not eligible target population. [pmid: 12411652].
1668 Hu KK, Boyko EJ, Scholes D, et al. Risk factors for urinary tract infections in postmenopausal women. Arch Intern Med. May. 10. 2004;164(9):989-93. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15136308].
1669 Hu TW. Impact of urinary incontinence on health-care costs. J Am Geriatr Soc. Mar. 1990;38(3):292-5. Comment. [pmid: 2313010].
1670 Hu TW, Kaltreider DL, Igou JF, et al. Cost effectiveness of training incontinent elderly in nursing homes: a randomized clinical trial. Health Serv Res. Aug. 1990;25(3):455-77. Not eligible target population. [pmid: 2116385].
1671 Hu TW, Wagner TH. Health-related consequences of overactive bladder: an economic perspective. BJU Int. Sep. 2005;96(Suppl 1):43-5. Not eligible target population. [pmid: 16086679].
1672 Hu TW, Wagner TH, Bentkover JD, et al. Estimated economic costs of overactive bladder in the United States. Urology. Jun. 2003;61(6):1123-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12809878].
1673 Hu TW, Wagner TH, Bentkover JD, et al. Costs of urinary incontinence and overactive bladder in the United States: a comparative study. Urology. Mar. 2004;63(3):461-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15028438].
1674 Huang AJ, Brown JS, Kanaya AM, et al. Quality-of-life impact and treatment of urinary incontinence in ethnically diverse older women. Arch Intern Med. Oct. 9. 2006;166(18):2000-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17030834].
1675 Huang AJ, Subak LL, Wing R, et al. An intensive behavioral weight loss intervention and hot flushes in women. Arch Intern Med. Jul. 12. 2010;170(13):1161-7. Not eligible outcomes. [pmid: 20625026].
1676 Huang YH, Lin AT, Chen KK, et al. High failure rate using allograft fascia lata in pubovaginal sling surgery for female stress urinary incontinence. Urology. Dec. 2001;58(6):943-6. Not eligible exposure. [pmid: 11744464].
1677 Hubner M, Hetzer F, Weishaupt D, et al. A prospective comparison between clinical outcome and open-configuration magnetic resonance defecography findings before and after surgery for symptomatic rectocele. Colorectal Dis. Sep. 2006;8(7):605-11. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16919115].
1678 Hubner WA, Schlarp OM. Treatment of incontinence after prostatectomy using a new minimally invasive device: adjustable continence therapy. BJU Int. Sep. 2005;96(4):587-94. Not eligible target population. [pmid: 16104915].
1679 Huebner W, Kocjancic E, Rocha FT, et al. International Long Term Evaluation of the Adjustable Continence Therapy (ProACT) for Male Post Prostatectomy Stress Urinary Incontinence. Paper presented at: 2008 Annual Meeting of the American Urological Association. Orlando, Florida (USA). 17–22 May 2008. Not eligible target population.
1680 Hughes KM. Measurement of Oxybutynin and its N-desethyl metabolit in plasma, and its application to pharmacokinetic studies in young, elderly and frail elderly volunteers. Xenobiotica. 1992;22(7):859-69. Not eligible target population. [pmid: 1455904].
1681 Hui-Chi H. A checklist for assessing the risk of falls among the elderly. J Nurs Res. Jun. 2004;12(2):131-42. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15208777].
1682 Hullfish KL, Bovbjerg VE, Gibson J, et al. Patient-centered goals for pelvic floor dysfunction surgery: what is success, and is it achieved?. Am J Obstet Gynecol. Jul. 2002;187(1):88-92. Not eligible exposure. [pmid: 12114893].
1683 Hullfish KL, Bovbjerg VE, Steers WD. Patient-centered goals for pelvic floor dysfunction surgery: long-term follow-up. Am J Obstet Gynecol. Jul. 2004;191(1):201-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15295366].
1684 Hullfish KL, Bovbjerg VE, Steers WD. Colpocleisis for pelvic organ prolapse: patient goals, quality of life, and satisfaction. Obstet Gynecol. Aug. 2007;110(2 Pt 1):341-5. Not eligible exposure. [pmid: 17666609].
1685 Hundley AF, Brown MB, Brubaker L, et al. A multicentered comparison of measurements obtained with microtip and external water pressure transducers. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2006;17(4):400-6. no associated hypothesis tested. [pmid: 16284710].
1686 Hung MJ, Liu FS, Shen PS, et al. Analysis of two sling procedures using polypropylene mesh for treatment of stress urinary incontinence. Int J Gynaecol Obstet. Feb. 2004;84(2):133-41. Not eligible exposure. [pmid: 14871515].
1687 Hunskaar S. One hundred and fifty men with urinary incontinence. II. Help seeking and self care. Scand J Prim Health Care. Mar. 1992;10(1):26-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 1589659].
1688 Hunskaar S, Lose G, Sykes D, et al. The prevalence of urinary incontinence in women in four European countries. BJU Int. Feb. 2004;93(3):324-30. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14764130].
1689 Hunskaar S, Sandvik H. One hundred and fifty men with urinary incontinence. III. Psychosocial consequences. Scand J Prim Health Care. Sep. 1993;11(3):193-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8272651].
1690 Hunskaar S, Vinsnes A. The quality of life in women with urinary incontinence as measured by the sickness impact profile. J Am Geriatr Soc. Apr. 1991;39(4):378-82. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 2010587].
1691 Hunter KF, Moore KN, Allen M. Lower urinary tract symptoms in older adults undergoing hip arthroplasty: a feasibility study. J Wound Ostomy Continence Nurs. May–Jun. 2008;35(3):334-40. Not eligible target population. [pmid: 18496092].
1692 Hunter S, Anderson J, Hanson D, et al. Clinical trial of a prevention and treatment protocol for skin breakdown in two nursing homes. Journal of Wound, Ostomy, & Continence Nursing. 2003:250-8. Not eligible target population.
1693 Hunter-Smith D, Pappas C, Devarajan S. Clinical inquiries. How can you best diagnose idiopathic normal pressure hydrocephalus?. Journal of Family Practice. Nov. 2007;56(11):947-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17976345].
1694 Hurley RM, Harris D, Shepherd RR. Incontinence in myelodysplasia: imipramine hydrochloride revisited. Clin Pediatr (Phila). Aug. 2000;39(8):489-91. Not eligible target population. [pmid: 10961822].
1695 Hussar DA. New drugs: palifermin, eszopiclone, and darifenacin hydrobromide. J Am Pharm Assoc. 2005. Mar–Apr. 2003;45(2):301-3. Comment. [pmid: 15868764].
1696 Hussar DA. New drugs: acamprosate calcium and solifenacin succinate. J Am Pharm Assoc. 2005. Jan–Feb. 2003;45(1):109-11. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15730126].
1697 Hussar DA. New drugs 06, part I. Nursing. Feb. 2006;36(2):54-61. quiz 2–3. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16462265].
1698 Hyams G, McCoull K, Smith PS, et al. Behavioural continence training in mental handicap: a 10-year follow-up study. J Intellect Disabil Res. Dec. 1992;36(Pt 6):551-8. Not eligible target population. [pmid: 1477492].
1699 Iglesias X, Espuna M, Puig M, et al. Pubic bone anchoring devices for the surgical treatment of urinary stress incontinence in patients with severe genital prolapse. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(5):314-8. Not eligible exposure. [pmid: 12355292].
1700 Ignjatovic I, Vuckovic M, Srzentic Z. Transobturatory tension-free composite sling for urethral support in patients with stress urinary incontinence: favorable experience after 1 year follow up. Int J Urol. Jun. 2006;13(6):728-32. Not eligible exposure. [pmid: 16834651].
1701 Ijland MM, Fischer DC, Kieback DG, et al. Midline intravaginal slingplasty for treatment of urinary stress incontinence: results of an independent audit up to 2 years after surgery. Int Urogynecol J Pelvic Floor Dysfunct. Nov–Dec. 2005;16(6):447-54. Not eligible exposure. [pmid: 15742119].
1702 Iliffe S, Tai SS, Haines A, et al. Are elderly people living alone an at risk group?. BMJ. Oct. 24. 1992;305(6860):1001-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 1458108].
1703 Imamoglu MA, Tuygun C, Bakirtas H, et al. The comparison of artificial urinary sphincter implantation and endourethral macroplastique injection for the treatment of postprostatectomy incontinence. Eur Urol. Feb. 2005;47(2):209-13. Not eligible target population. [pmid: 15661416].
1704 Indrekvam S, Fosse OA, Hunskaar S. A Norwegian national cohort of 3198 women treated with home-managed electrical stimulation for urinary incontinence--demography and medical history. Scand J Urol Nephrol. Feb. 2001;35(1):26-31. no associative hypothesis tested. [pmid: 11291683].
1705 Indrekvam S, Hunskaar S. Home electrical stimulation for urinary incontinence: a study of the diffusion ofa new technology. Urology. Oct. 2003;62(4 Suppl 1):24-30. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14550834].
1706 Innerkofler PC, Guenther V, Rehder P, et al. Improvement of quality of life, anxiety and depression after surgery in patients with stress urinary incontinence: results of a longitudinal short-term follow-up. Health Qual Life Outcomes. 2008;6:72. Not eligible exposure. [pmid: 18823552].
1707 Inzitari M, Pozzi C, Ferrucci L, et al. Subtle neurological abnormalities as risk factors for cognitive and functional decline, cerebrovascular events, and mortality in older community-dwelling adults. Arch Intern Med. Jun. 23. 2008;168(12):1270-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18574083].
1708 Iosif CS. Effects of protracted administration of estriol on the lower genito urinary tract in postmenopausal women. Arch Gynecol Obstet. 1992;251(3):115-20. Case-series. [pmid: 1605675].
1709 Ip V. Evaluation of a patient education tool to reduce the incidence of incontinence post-prostate surgery. Urol Nurs. Oct. 2004;24(5):401-7. Not eligible target population. [pmid: 15575109].
1710 Irwin B. User support groups in continence care. Nurs Times. Aug. 3. 2000;96(31 Suppl):24. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11963701].
1711 Irwin DE, Abrams P, Milsom I, et al. Understanding the elements of overactive bladder: questions raised by the EPIC study. BJU Int. Jun. 2008;101(11):1381-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18336602].
1712 Irwin DE, Milsom I, Kopp Z, et al. Symptom bother and health care-seeking behavior among individuals with overactive bladder. Eur Urol. May. 2008;53(5):1029-37. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18243515].
1713 Irwin DE, Milsom I, Reilly K, et al. Overactive bladder is associated with erectile dysfunction and reduced sexual quality of life in men. J Sex Med. Dec. 2008;5(12):2904-10. Not eligible target population. [pmid: 19090944].
1714 Irwin DE, Mungapen L, Milsom I, et al. The economic impact of overactive bladder syndrome in six Western countries. BJU Int. Jan. 2009;103(2):202-9. Not eligible target population. [pmid: 19278532].
1715 Isambert JL, Egon G, Colombel P. Adjuvant drug therapy: a review of 30 cases of sacral anterior root stimulator. Neurourol Urodyn. 1993;12(5):513-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8252061].
1716 Isherwood PJ, Rane A. Comparative assessment of pelvic floor strength using a perineometer and digital examination. BJOG. Aug. 2000;107(8):1007-11. Not eligible outcomes. [pmid: 10955433].
1717 Ishikawa M. Clinical guidelines for idiopathic normal pressure hydrocephalus. Neurol Med Chir (Tokyo). Apr. 2004;44(4):222-3. Not eligible target population. [pmid: 15185767].
1718 Ishikawa M, Hashimoto M, Kuwana N, et al. Guidelines for management of idiopathic normal pressure hydrocephalus. Neurologia medico-chirurgica. 2008;48(Suppl):S1-23. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18408356].
1719 Ishiko O, Ushiroyama T, Saji F, et al. beta(2)-adrenergic agonists and pelvic floor exercises for female stress incontinence. Int J Gynaecol Obstet. Oct. 2000;71(1):39-44. Not eligible exposure. [pmid: 11044540].
1720 Iskandar BJ, Fulmer BB, Hadley MN, et al. Congenital tethered spinal cord syndrome in adults. J Neurosurg. Jun. 1998;88(6):958-61. Not eligible target population. [pmid: 9609288].
1721 Iskander MN, Kapoor DS, Mohammed A. Subjective outcomes of the TVT procedure. Int J Gynaecol Obstet. Oct. 2003;83(1):69-70. Not eligible exposure. [pmid: 14511876].
1722 Ismail SI. Radiofrequency remodelling of the endopelvic fascia is not an effective procedure for urodynamic stress incontinence in women. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2008;19(9):1205-9. Not eligible exposure. [pmid: 18504516].
1723 Isom-Batz G, Zimmern PE. Collagen injection for female urinary incontinence after urethral or periurethral surgery. Journal of Urology. Feb. 2009;181(2):701-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 19091340].
1724 Itano N, Berman CJ, Rodriguez LV, et al. Polypropylene sling for the treatment of stress urinary incontinence: intermediate term results. Journal of Urology. 2003;169S:270. Not eligible exposure.
1725 Jack GS, Almeida FG, Zhang R, et al. Processed lipoaspirate cells for tissue engineering of the lower urinary tract: implications for the treatment of stress urinary incontinence and bladder reconstruction. J Urol. Nov. 2005;174(5):2041-5. Not eligible target population. [pmid: 16217390].
1726 Jackson RA, Vittinghoff E, Kanaya AM, et al. Urinary incontinence in elderly women: findings from the Health, Aging, and Body Composition Study. Obstet Gynecol. Aug. 2004;104(2):301-7. Not eligible target population. [pmid: 15292003].
1727 Jackson S. Female urinary incontinence symptom evaluation and diagnosis. European Urology. 1997;32(SUPPL 2):20-4. Not eligible review. [pmid: 9248808].
1728 Jackson SL, Boyko EJ, Scholes D, et al. Predictors of urinary tract infection after menopause: a prospective study. Am J Med. Dec. 15. 2004;117(12):903-11. Not eligible target population. [pmid: 15629728].
1729 Jackson SL, Scholes D, Boyko EJ, et al. Urinary incontinence and diabetes in postmenopausal women. Diabetes Care. Jul. 2005;28(7):1730-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15983327].
1730 Jackson SL, Scholes D, Boyko EJ, et al. Predictors of urinary incontinence in a prospective cohort of postmenopausal women. Obstet Gynecol. Oct. 2006;108(4):855-62. Not eligible target population. [pmid: 17012446].
1731 Jacobsen NE, Moore KN, Estey E, et al. Open versus laparoscopic radical prostatectomy: a prospective comparison of postoperative urinary incontinence rates. J Urol. Feb. 2007;177(2):615-9. Not eligible target population. [pmid: 17222646].
1732 Jain R, Radhapyari K, Jadon N. Adsorptive stripping voltammetric behavior and determination of anticholinergic agent oxybutynin chloride on a mercury electrode. J Colloid Interface Sci. Oct. 15. 2007;314(2):572-7. Not eligible target population. [pmid: 17618643].
1733 Jakimiuk AJ, Maciejewski T, Fritz A, et al. Surgical treatment of stress urinary incontinence using the tension-free vaginal tape-obturator system (TVT-O) technique. Eur J Obstet Gynecol Reprod Biol. Nov. 2007;135(1):127-31. Not eligible exposure. [pmid: 17466437].
1734 Jakobsen H, Kromann-Andersen B, Nielsen KK, et al. Pad weighing tests with 50% or 75% bladder filling. Does it matter?. Acta Obstet Gynecol Scand. Jul. 1993;72(5):377-81. Not eligible exposure. [pmid: 8392270].
1735 Jameson JS, Speakman CT, Darzi A, et al. Audit of postanal repair in the treatment of fecal incontinence. Dis Colon Rectum. Apr. 1994;37(4):369-72. Not eligible Case-series. [pmid: 8168416].
1736 Jani AB, Hellman S. Early prostate cancer: hedonic prices model of provider-patient interactions and decisions. Int J Radiat Oncol Biol Phys. Mar. 15. 2008;70(4):1158-68. Not eligible target population. [pmid: 17881151].
1737 Jansen L, Forbes D. The psychometric testing of a urinary incontinence nursing assessment instrument. J Wound Ostomy Continence Nurs. Jan–Feb. 2006;33(1):69-76. Not eligible target population. [pmid: 16444108].
1738 Jarmy-Di Bella ZI, Girao MJ, Di Bella V, et al. Hormonal influence on periurethral vessels in postmenopausal incontinent women using Doppler velocimetry analysis. Maturitas. Mar. 20. 2007;56(3):297-302. Not eligible outcomes. [pmid: 17092664].
1739 Jarow JP. Puboprostatic ligament sparing radical retropubic prostatectomy. Semin Urol Oncol. Feb. 2000;18(1):28-32. Not eligible target population. [pmid: 10719927].
1740 Jarvis SK, Hallam TK, Lujic S, et al. Peri-operative physiotherapy improves outcomes for women undergoing incontinence and or prolapse surgery: results of a randomised controlled trial. Aust N Z J Obstet Gynaecol. Aug. 2005;45(4):300-3. Not eligible exposure. [pmid: 16029296].
1741 Jawad SH, Ward AB, Jones P. Study of the relationship between premorbid urinary incontinence and stroke functional outcome. Clin Rehabil. Oct. 1999;13(5):447-52. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10498352].
1742 Jawaheer G, Rangecroft L. The Pippi Salle procedure for neurogenic urinary incontinence in childhood: a three-year experience. Eur J Pediatr Surg. Dec. 1999;9(Suppl 1):9-11. Not eligible target population. [pmid: 10661782].
1743 Jeffery S, Fynes M, Lee F, et al. Efficacy and complications of intradetrusor injection with botulinum toxin A in patients with refractory idiopathic detrusor overactivity. BJU international. Dec. 2007;100(6):1302-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17979928].
1744 Jelovsek JE, Barber MD. Women seeking treatment for advanced pelvic organ prolapse have decreased body image and quality of life. Am J Obstet Gynecol. May. 2006;194(5):1455-61. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16647928].
1745 Jelovsek JE, Barber MD, Karram MM, et al. Randomised trial of laparoscopic Burch colposuspension versus tension-free vaginal tape: long-term follow up. BJOG. Jan. 2008;115(2):219-25. discussion 25. Not eligible exposure. [pmid: 18081602].
1746 Jeong SH, Kim JH, Ahn YM, et al. A 2-year prospective follow-up study of lower urinary tract symptoms in patients treated with clozapine. J Clin Psychopharmacol. Dec. 2008;28(6):618-24. Not eligible target population. [pmid: 19011429].
1747 Jervis LL. The pollution of incontinence and the dirty work of caregiving in a U.S. nursing home. Med Anthropol Q. Mar. 2001;15(1):84-99. Not eligible target population. [pmid: 11288620].
1748 Jeter KF, Wagner DB. Incontinence in the American home. A survey of 36,500 people. J Am Geriatr Soc. Mar. 1990;38(3):379-83. Not eligible exposure. [pmid: 2313016].
1749 Jewart RD, Green J, Lu CJ, et al. Cognitive, behavioral, and physiological changes in Alzheimer disease patients as a function of incontinence medications. Am J Geriatr Psychiatry. Apr. 2005;13(4):324-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15845759].
1750 Jha S, Moran P, Greenham H, et al. Sexual function following surgery for urodynamic stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2007;18(8):845-50. Not eligible exposure. [pmid: 17115231].
1751 Jha S, Toozs-Hobson P, Parsons M, et al. Does preoperative urodynamics change the management of prolapse?. Journal of Obstetrics & Gynaecology. Apr. 2008;28(3):320-2. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18569478].
1752 Jirovec MM, Jenkins J, Isenberg M, et al. Urine control theory derived from Roy’s conceptual framework. Nurs Sci Q. Jul. 1999;12(3):251-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11847672].
1753 Jitapunkul S, Hanvivadhanakul P. Outcomes and predicting factors of mortality among newly admitted female medical inpatients. J Med Assoc Thai. Jul. 1998;81(7):491-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9676085].
1754 Johanson RB, Heycock E, Carter J, et al. Maternal and child health after assisted vaginal delivery: five-year follow up of a randomised controlled study comparing forceps and ventouse. Br J Obstet Gynaecol. Jun. 1999;106(6):544-9. Not eligible target population. [pmid: 10426611].
1755 Johansson C, Hellstrom L, Ekelund P, et al. Urinary incontinence: a minor risk factor for hip fractures in elderly women. Maturitas. Aug. 1996;25(1):21-8. Not eligible target population. [pmid: 8887305].
1756 John H. Bulbourethral composite suspension:: a new operative technique for post-prostatectomy incontinence. J Urol. May. 2004;171(5):1866-70. discussion 9–70. Not eligible target population. [pmid: 15076295].
1757 John H, Blick N. Mid-term outcome after bulbourethral composite suspension for postprostatectomy incontinence. Urology. Jun. 2008;71(6):1191-5. Not eligible exposure. [pmid: 18538695].
1758 Johnson TM 2nd, Kincade JE, Bernard SL, et al. Self-care practices used by older men and women to manage urinary incontinence: results from the national follow-up survey on self-care and aging. J Am Geriatr Soc. Aug. 2000;48(8):894-902. Not eligible outcomes. [pmid: 10968292].
1759 Johnson TM 2nd, Kincade JE, Bernard SL, et al. The association of urinary incontinence with poor self-rated health. J Am Geriatr Soc. Jun. 1998;46(6):693-9. Not eligible exposure. [pmid: 9625183].
1760 Johnson TM, Miller M, Tang T, et al. Oral ddAVP for nighttime urinary incontinence in characterized nursing home residents: a pilot study. Journal of the American Medical Directors Association. 2006:6-11. Not eligible target population. [pmid: 16413428].
1761 Johnson TM 2nd, Ouslander JG. The newly revised F-Tag 315 and surveyor guidance for urinary incontinence in long-term care. J Am Med Dir Assoc. Nov. 2006;7(9):594-600. Not eligible target population. [pmid: 17095426].
1762 Johnson TM, Ouslander JG, Uman GC, et al. Urinary incontinence treatment preferences in long-term care. J Am Geriatr Soc. Jun. 2001;49(6):710-8. Not eligible target population. [pmid: 11454108].
1763 Jolic V, Gilja I. Vaginal vs. transabdominal ultrasonography in the evaluation of female urinary tract anatomy, stress urinary incontinence and pelvic organs static disturbances. Zentralbl Gynakol. 1997;119(10):483-91. Not eligible exposure. [pmid: 9361397].
1764 Joly F, Brune D, Couette JE, et al. Health-related quality of life and sequelae in patients treated with brachytherapy and external beam irradiation for localized prostate cancer. Ann Oncol. Jul. 1998;9(7):751-7. Not eligible target population. [pmid: 9739442].
1765 Jones D, Perese EF. Promoting self-management of urinary incontinence in a geropsychiatric day treatment program. J Psychosoc Nurs Ment Health Serv. May. 2003;41(5):38-43. not eligible outcomes. [pmid: 12743965].
1766 Jones F. The accuracy of predicting functional recovery in patients following a stroke, by physiotherapists and patients. Physiother Res Int. 1998;3(4):244-56. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9859133].
1767 Jones JS, Vasavada SP, Rackley RR. Prospective randomized controlled trial of modified hypermobility test for urinary incontinence. Journal of Pelvic Medicine and Surgery. 2007:13-7. Not eligible exposure.
1768 Jongen VH, Brouwer WK. Comparison of the modified Pereyra procedure using permanent suture material and Burch urethropexy. Eur J Obstet Gynecol Reprod Biol. May. 1999;84(1):7-11. Not eligible exposure. [pmid: 10413219].
1769 Jonler M, Madsen FA, Rhodes PR, et al. A prospective study of quantification of urinary incontinence and quality of life in patients undergoing radical retropubic prostatectomy. Urology. Sep. 1996;48(3):433-40. Not eligible target population. [pmid: 8804498].
1770 Jonler M, Messing EM, Rhodes PR, et al. Sequelae of radical prostatectomy. Br J Urol. Sep. 1994;74(3):352-8. Not eligible target population. [pmid: 7953267].
1771 Jonler M, Nielsen OS, Wolf H. Urinary symptoms, potency, and quality of life in patients with localized prostate cancer followed up with deferred treatment. Urology. Dec. 1998;52(6):1055-62. discussion 63. Not eligible target population. [pmid: 9836554].
1772 Jonler M, Ritter MA, Brinkmann R, et al. Sequelae of definitive radiation therapy for prostate cancer localized to the pelvis. Urology. Dec. 1994;44(6):876-82. Not eligible target population. [pmid: 7985316].
1773 Jonsson S, Karlsson MO. Estimation of dosing strategies aiming at maximizing utility or responder probability, using oxybutynin as an example drug. Eur J Pharm Sci. May. 2005;25(1):123-32. Secondary data analysis. [pmid: 15854808].
1774 Joseph AC. Noninvasive therapies for treating post-prostatectomy urinary incontinence. Urol Nurs. Aug. 2006;26(4):271-5. 69. quiz 6. Not eligible target population. [pmid: 16939044].
1775 Joseph AC, Chang MK. Comparison of behavior therapy methods for urinary incontinence following prostate surgery: a pilot study. Urol Nurs. Jun. 2000;20(3):203-4. Not eligible target population. [pmid: 11998139].
1776 Ju CC, Swan LK, Merriman A, et al. Urinary incontinence among the elderly people of Singapore. Age Ageing. Jul. 1991;20(4):262-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 1927732].
1777 Juang CM, Yu KJ, Chou P, et al. Efficacy analysis of trans-obturator tension-free vaginal tape (TVT-O) plus modified Ingelman-Sundberg procedure versus TVT-O alone in the treatment of mixed urinary incontinence: a randomized study. Eur Urol. Jun. 2007;51(6):1671-8. discussion 9. Not eligible exposure. [pmid: 17254697].
1778 Juma S, Brito CG. Transobturator tape (TOT): Two years follow-up. Neurourol Urodyn. 2007;26(1):37-41. Not eligible exposure. [pmid: 17083100].
1779 Jumadilova Z, Zyczynski T, Paul B, et al. Urinary incontinence in the nursing home: resident characteristics and prevalence of drug treatment. American Journal of Managed Care. Jul. 2005;11(4 Suppl):S112-20. Not eligible target population. [pmid: 16161384].
1780 Jung BH, Bai SW, Chung BC. Urinary profile of endogenous steroids in postmenopausal women with stress urinary incontinence. J Reprod Med. Nov. 2001;46(11):969-74. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11762153].
1781 Jung HC, Kim HT, Song PH, et al. Experience of REMEEX system for the treatment of female urinary incontinence, intrinsic sphinteric deficiency and neurogenic bladder. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Not eligible exposure.
1782 Jung M, Faltin DL, Rutschmann O. Impact of urinary incontinence in community-dwelling women. Rev Med Suisse. Oct. 18. 2006;2(83):2332-5. Not eligible language. [pmid: 17112083].
1783 Kafri R, Katz-Leurer M, Dvir Z, et al. Rehabilitation vs Drug Therapy for Urge Urinary Incontinence, the Short and the Long Term Outcome. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep –3 Oct 2009. Not eligible case series.
1784 Kafri R, Langer R, Dvir Z, et al. Rehabilitation vs drug therapy for urge urinary incontinence: short-term outcome. International Urogynecology Journal. Apr. 2007;18(4):407-11. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 21145].
1785 Kafri R, Shames J, Raz M, et al. Rehabilitation versus drug therapy for urge urinary incontinence: long-term outcomes. International Urogynecology Journal. Jan. 2008;19(1):47-52. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 21136].
1786 Kajbafzadeh A, Mahboubi AH, Payabvash S. Concomitant repeated intravesical injections of botulinum toxin-type A and laparoscopic antegrade continence enema; a new solution for an old problem. BJU Int. May. 2009;103(9):1248-54. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 19154454].
1787 Kajbafzadeh AM, Elmi A, Payabvash S, et al. Transurethral autologous myoblast injection for treatment of urinary incontinence in children with classic bladder exstrophy. J Urol. Sep. 2008;180(3):1098-105. Not eligible target population. [pmid: 18639289].
1788 Kajbafzadeh AM, Moosavi S, Tajik P, et al. Intravesical injection of botulinum toxin type A: management of neuropathic bladder and bowel dysfunction in children with myelomeningocele. Urology. Nov. 2006;68(5):1091-6. discussion 6–7. Not eligible target population. [pmid: 17113899].
1789 Kajiwara M, Kato M, Mutaguchi K, et al. Overactive bladder in children should be strictly differentiated from monosymptomatic nocturnal enuresis. Urologia internationalis. 2008;80(1):57-61. Not eligible target population. [pmid: 18204235].
1790 Kalble T, Roth S. Serosa lined and tapered ileum as primary and secondary continence mechanism for various catheterizable pouches. J Urol. Nov. 2008;180(5):2053-7. Not eligible exposure. [pmid: 18804246].
1791 Kalpakjian CZ, Scelza WM, Forchheimer MB, et al. Preliminary reliability and validity of a Spinal Cord Injury Secondary Conditions Scale. J Spinal Cord Med. 2007;30(2):131-9. Not eligible target population. [pmid: 17591225].
1792 Kalsi V, Apostolidis A, Popat R, et al. Quality of life changes in patients with neurogenic versus idiopathic detrusor overactivity after intradetrusor injections of botulinum neurotoxin type A and correlations with lower urinary tract symptoms and urodynamic changes. Eur Urol. Mar. 2006;49(3):528-35. not eligible target population. [pmid: 16426735].
1793 Kalsi V, Gonzales G, Popat R, et al. Botulinum injections for the treatment of bladder symptoms of multiple sclerosis. Annals of Neurology. Nov. 2007;62(5):452-7. Not eligible target population. [pmid: 17890635].
1794 Kammerer-Doak DN, Dorin MH, Rogers RG, et al. A randomized trial of burch retropubic urethropexy and anterior colporrhaphy for stress urinary incontinence. Obstet Gynecol. Jan. 1999;93(1):75-8. Not eligible exposure. [pmid: 9916960].
1795 Kammerer-Doak DN, Rogers RG, Bellar B. Vaginal erosion of cadaveric fascia lata following abdominal sacrocolpopexy and suburethral sling urethropexy. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(2):106-9. discussion 9. Not eligible exposure. [pmid: 12054177].
1796 Kanai A, de Groat W, Birder L, et al. Symposium report on urothelial dysfunction: pathophysiology and novel therapies. J Urol. May. 2006;175(5):1624-9. Symposium. [pmid: 16600715].
1797 Kane L, Chung T, Lawrie H, et al. The pubofascial anchor sling procedure for recurrent genuine urinary stress incontinence. BJU Int. Jun. 1999;83(9):1010-4. Not eligible exposure. [pmid: 10368246].
1798 Kang Y. Knowledge and attitudes about urinary incontinence among community-dwelling Korean American women. J Wound Ostomy Continence Nurs. Mar–Apr. 2009;36(2):194-9. Not eligible outcomes. [pmid: 19287269].
1799 Kao TC, Cruess DF, Garner D, et al. Multicenter patient self-reporting questionnaire on impotence, incontinence and stricture after radical prostatectomy. J Urol. Mar. 2000;163(3):858-64. Not eligible target population. [pmid: 10687992].
1800 Kaplan HJ, Mamo GJ. Pubovaginal sling technique utilizing a unique bone anchor instrumentation system. Can J Urol. Oct. 2000;7(5):1116-21. Not eligible exposure. [pmid: 11114875].
1801 Kaplan SA, Roehrborn CG, Chancellor M, et al. Extended-release tolterodine with or without tamsulosin in men with lower urinary tract symptoms and overactive bladder: effects on urinary symptoms assessed by the International Prostate Symptom Score. BJU Int. Nov. 2008;102(9):1133-9. Not eligible target population. [pmid: 18510659].
1802 Kaplan SA, Roehrborn CG, Dmochowski R, et al. Tolterodine extended release improves overactive bladder symptoms in men with overactive bladder and nocturia. Urology. Aug. 2006;68(2):328-32. Not eligible target population. [pmid: 16904446].
1803 Kaplan SA, Roehrborn CG, Rovner ES, et al. Tolterodine and tamsulosin for treatment of men with lower urinary tract symptoms and overactive bladder: a randomized controlled trial. JAMA. Nov. 15. 2006;296(19):2319-28. Not eligible target population. [pmid: 17105794].
1804 Kaplan SA, Walmsley K, Te AE. Tolterodine extended release attenuates lower urinary tract symptoms in men with benign prostatic hyperplasia. J Urol. Dec. 2005;174(6):2273-5. discussion 5–6. Not eligible target population. [pmid: 16280803].
1805 Kaplinsky R, Greenfield S, Wan J, et al. Expanded followup of intravesical oxybutynin chloride use in children with neurogenic bladder. J Urol. Aug. 1996;156(2 Pt 2):753-6. Not eligible target population. [pmid: 8683776].
1806 Kapoor DS, Davila GW, Rosenthal RJ, et al. Pelvic floor dysfunction in morbidly obese women: pilot study. Obes Res. Jul. 2004;12(7):1104-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15292474].
1807 Kapoor DS, Sultan AH, Thakar R, et al. Management of complex pelvic floor disorders in a multidisciplinary pelvic floor clinic. Colorectal Dis. Feb. 2008;10(2):118-23. Not eligible outcomes. [pmid: 18199292].
1808 Kapoor R, Dubey D, Kumar A, et al. Modified bulbar urethral sling procedure for the treatment of male sphincteric incontinence. J Endourol. Jun. 2001;15(5):545-9. Not eligible target population. [pmid: 11465337].
1809 Karantanis E, Fynes M, Moore KH, et al. Comparison of the ICIQ-SF and 24-hour pad test with other measures for evaluating the severity of urodynamic stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2004;15(2):111-6. discussion 6. Not eligible outcomes. [pmid: 15014938].
1810 Karantanis E, Fynes MM, Stanton SL. The tension-free vaginal tape in older women. BJOG. Aug. 2004;111(8):837-41. Not eligible exposure. [pmid: 15270933].
1811 Karlowicz KA. Evaluation of the Urinary Incontinence Scales to measure change after experiential learning: a pilot study. Urol Nurs. Jan–Feb. 2009;29(1):40-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 19331275].
1812 Karlowicz KA, Palmer KL. Engendering student empathy for disabled clients with urinary incontinence through experiential learning. Urol Nurs. Oct. 2006;26(5):373-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17078325].
1813 Karon S. A team approach to bladder retraining: a pilot study. Urol Nurs. Aug. 2005;25(4):269-76. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16225344].
1814 Karram MM, Partoll L, Rahe J. Efficacy of nonsurgical therapy for urinary incontinence. J Reprod Med. Apr. 1996;41(4):215-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8728070].
1815 Karsenty G, Reitz A, Lindemann G, et al. Persistence of therapeutic effect after repeated injections of botulinum toxin type A to treat incontinence due to neurogenic detrusor overactivity. Urology. Dec. 2006;68(6):1193-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17141831].
1816 Kato K, Yoshida K, Suzuki K, et al. Managing patients with an overactive bladder and glaucoma: a questionnaire survey of Japanese urologists on the use of anticholinergics. BJU Int. Jan. 2005;95(1):98-101. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15638904].
1817 Katz G, Rodriguez R. Use of a modified American Urological Association Symptom Score for the evaluation of the quality of life of patients with prostate cancer. Urology. Jan. 2001;57(1):112-6. Not eligible target population. [pmid: 11164154].
1818 Katz G, Rodriguez R. Changes in continence and health-related quality of life after curative treatment and watchful waiting of prostate cancer. Urology. Jun. 2007;69(6):1157-60. Not eligible target population. [pmid: 17572206].
1819 Kaufman MW. The WOC nurse: economic, quality of life, and legal benefits. Dermatol Nurs. Jun. 2001;13(3):215-9. 22. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11917456].
1820 Kaufman MW, Bajracharya S. Enterostomal therapy nursing in Nepal. J Wound Ostomy Continence Nurs. Sep. 2000;27(5):255-6. Not eligible target population. [pmid: 10999962].
1821 Kay GG, Wesnes KA. Pharmacodynamic effects of darifenacin, a muscarinic M selective receptor antagonist for the treatment of overactive bladder, in healthy volunteers. BJU Int. Nov. 2005;96(7):1055-62. Not eligible target population. [pmid: 16225528].
1822 Kaya H, Sezik M, Ozbasar D, et al. Intrafascial versus extrafascial abdominal hysterectomy: effects on urinary urge incontinence. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2004;15(3):171-4. Not eligible target population. [pmid: 15167995].
1823 Kaye KW. Changing trends in urology practice: increasing outpatient surgery. Aust N Z J Surg. Jan. 1995;65(1):31-4. Not eligible target population. [pmid: 7818420].
1824 Keachie J. Continence. Island life. Nurs Times. Sep 29–Oct 5. 1993;89(39):72. 4. 6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8415106].
1825 Keane DP, Winder A, Lewis P, et al. A combined urodynamic and continence unit--a review of the first 19 years. Br J Urol. Feb. 1993;71(2):161-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8461948].
1826 Keepnews D, Capitman JA, Rosati RJ. Measuring patient-level clinical outcomes of home health care. J Nurs Scholarsh. 2004;36(1):79-85. Not eligible exposure. [pmid: 15098423].
1827 Keil K. Urogenital atrophy: diagnosis, sequelae, and management. Curr Womens Health Rep. Aug. 2002;2(4):305-11. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12150759].
1828 Kelleher CJ, Cardozo L, Chapple CR, et al. Improved quality of life in patients with overactive bladder symptoms treated with solifenacin. BJU Int. Jan. 2005;95(1):81-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15638900].
1829 Kelleher CJ, Cardozo LD, Khullar V, et al. A medium-term analysis of the subjective efficacy of treatment for women with detrusor instability and low bladder compliance. Br J Obstet Gynaecol. Sep. 1997;104(9):988-93. Not eligible exposure. [pmid: 9307522].
1830 Keller SL. Urinary incontinence: occurrence, knowledge, and attitudes among women aged 55 and older in a rural Midwestern setting. J Wound Ostomy Continence Nurs. Jan. 1999;26(1):30-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10036422].
1831 Kelly J. Inter-rater reliability and Waterlow’s pressure ulcer risk assessment tool. Nurs Stand. Apr. 20–26. 2005;19(32):86-7. 90. 2. no associative hypothesis tested. [pmid: 15875591].
1832 Kelly M, Tan BK, Thompson J, et al. Healthy adults can more easily elevate the pelvic floor in standing than in crook-lying: an experimental study. Aust J Physiother. 2007;53(3):187-91. Not eligible target population. [pmid: 17725476].
1833 Kenton K, Brincat C, Mutone M, et al. Repeat cesarean section and primary elective cesarean section: recently trained obstetrician-gynecologist practice patterns and opinions. Am J Obstet Gynecol. Jun. 2005;192(6):1872-5. discussion 5–6. Not eligible target population. [pmid: 15970836].
1834 Kenton K, Fitzgerald MP, Brubaker L. What is a clinician to do-believe the patient or her urinary diary?. J Urol. Aug. 2006;176(2):633-5. discussion 5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16813908].
1835 Kenton K, Mueller ER. The global burden of female pelvic floor disorders. BJU Int. Sep. 2006;98(Suppl 1):1-5. discussion 6–7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16911592].
1836 Kenton K, Sadowski D, Shott S, et al. A comparison of women with primary and recurrent pelvic prolapse. Am J Obstet Gynecol. Jun. 1999;180(6 Pt 1):1415-8. Not eligible exposure. [pmid: 10368479].
1837 Kerfoot BP, Turek PJ. What every graduating medical student should know about urology: the stakeholder viewpoint. Urology. Apr. 2008;71(4):549-53. Not eligible target population. [pmid: 18387383].
1838 Keshtgar AS, Rickwood AM. Urological consequences of incomplete cord lesions in patients with myelomeningocele. Br J Urol. Aug. 1998;82(2):258-60. Not eligible target population. [pmid: 9722763].
1839 Kessler TM, Burkhard FC, Studer UE. Nerve-sparing open radical retropubic prostatectomy. Eur Urol. Jan. 2007;51(1):90-7. Not eligible target population. [pmid: 17074431].
1840 Khan MS, Chaliha C, Leskova L, et al. A randomized crossover trial to examine administration techniques related to the Bristol female lower urinary tract symptom (BFLUTS) questionnaire. Neurourol Urodyn. 2005;24(3):211-4. no associative hypothesis tested. [pmid: 15791603].
1841 Khastgir J, Hamid R, Arya M, et al. Surgical and patient reported outcomes of ‘clam’ augmentation ileocystoplasty in spinal cord injured patients. Eur Urol. Mar. 2003;43(3):263-9. Not eligible target population. [pmid: 12600429].
1842 Khorsandi M, Ginsberg PC, Harkaway RC. Reassessing the role of urodynamics after cerebrovascular accident. Males versus females. Urol Int. 1998;61(3):142-6. Not eligible target population. [pmid: 9933833].
1843 Khullar V, Abbot D, Cardoza LD, et al. Perineal ultrasound measurement of the urethral sphincter in women with urinary incontinence: An aid to diagnosis?. Paper presented at: Twenty-Fifth Annual Meeting of the British Medical Ultrasound Society. Eastbourne (UK). 7–9 Dec 1993. (World Meeting Number 934 5039). Not eligible outcomes.
1844 Kilic N, Balkan E, Akgoz S, et al. Comparison of the effectiveness and side-effects of tolterodine and oxybutynin in children with detrusor instability. Int J Urol. Feb. 2006;13(2):105-8. Not eligible target population. [pmid: 16563131].
1845 Kilonzo M, Vale L, Stearns SC, et al. Cost effectiveness of tension-free vaginal tape for the surgical management of female stress incontinence. Int J Technol Assess Health Care. Fall. 2004;20(4):455-63. Not eligible exposure. [pmid: 15609795].
1846 Kim HL, Gerber GS, Patel RV, et al. Practice patterns in the treatment of female urinary incontinence: a postal and internet survey. Urology. Jan. 2001;57(1):45-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11164141].
1847 Kim J. The development and evaluation of an incontinence intervention program for the elderly women at elderly welfare center. Taehan Kanho Hakhoe Chi. Dec. 2004;34(8):1427-33. no associative hypothesis tested. [pmid: 15687784].
1848 Kim JC, Chung BS, Choi JB, et al. A safety and quality of life analysis of intravaginal slingplasty in female stress incontinence: a prospective, open label, multicenter, and observational study. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2007;18(11):1331-5. Not eligible exposure. [pmid: 17333435].
1849 Kim JC, Park EY, Seo SI, et al. Nerve growth factor and prostaglandins in the urine of female patients with overactive bladder. J Urol. May. 2006;175(5):1773-6. discussion 6. Not eligible exposure. [pmid: 16600756].
1850 Kim JH, Rivas DA, Shenot PJ, et al. Intravesical resiniferatoxin for refractory detrusor hyperreflexia: a multicenter, blinded, randomized, placebo-controlled trial. The journal of spinal cord medicine. 2003;(4):358-63. Not eligible exposure. [pmid: 14992337].
1851 Kim JS, Lee EH, Park HC. Urinary incontinence: prevalence and knowledge among community-dwelling Korean women aged 55 and over. Taehan Kanho Hakhoe Chi. Jun. 2004;34(4):609-16. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15502426].
1852 Kim MR, Kim JH, Cho HH. Infracoccygeal sacropexy improves the quality of life of women with uterine prolapse. Maturitas. Feb. 20. 2008;59(2):158-62. Not eligible target population. [pmid: 18242893].
1853 Kim SP, Sarmast Z, Daignault S, et al. Long-term durability and functional outcomes among patients with artificial urinary sphincters: a 10-year retrospective review from the University of Michigan. J Urol. May. 2008;179(5):1912-6. Not eligible exposure. [pmid: 18353376].
1854 Kim Y, Yoshimura N, Masuda H, et al. Intravesical instillation of human urine after oral administration of trospium, tolterodine and oxybutynin in a rat model of detrusor overactivity. BJU Int. Feb. 2006;97(2):400-3. Not eligible target population. [pmid: 16430654].
1855 Kim YH, Kattan MW, Boone TB. Correlation of urodynamic results and urethral coaptation with success after transurethral collagen injection. Urology. Dec. 1997;50(6):941-8. Not eligible target population. [pmid: 9426727].
1856 Kim YH, Seo JT, Yoon H. The effect of overactive bladder syndrome on the sexual quality of life in Korean young and middle aged women. Int J Impot Res. Mar–Apr. 2005;17(2):158-63. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15510187].
1857 Kincade JE, Boyington AR, Lekan-Rutledge D, et al. Bladder management in adult care homes. Review of a program in North Carolina. J Gerontol Nurs. Oct. 2003;29(10):30-6. quiz 54–5. Not eligible target population. [pmid: 14558233].
1858 Kincade JE, Dougherty MC, Busby-Whitehead J, et al. Self-monitoring and pelvic floor muscle exercises to treat urinary incontinence. Urol Nurs. Oct. 2005;25(5):353-63. no primary result. [pmid: 16294613].
1859 Kincade JE, Dougherty MC, Carlson JR, et al. Factors related to urinary incontinence in community-dwelling women. Urol Nurs. Aug. 2007;27(4):307-17. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17877100].
1860 Kincade JE, Peckous BK, Busby-Whitehead J. A pilot study to determine predictors of behavioral treatment completion for urinary incontinence. Urol Nurs. Feb. 2001;21(1):39-44. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11998114].
1861 Kinchen KS, Burgio K, Diokno AC, et al. Factors associated with women’s decisions to seek treatment for urinary incontinence. Journal of Women’s Health. Sep. 2003;12(7):687-98. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 21156].
1862 Kinchen KS, Long S, Chang S, et al. The direct cost of stress urinary incontinence among women in a Medicaid population. Am J Obstet Gynecol. Dec. 2005;193(6):1936-44. Not eligible outcomes. [pmid: 16325594].
1863 Kinchen KS, Long S, Orsini L, et al. A retrospective claims analysis of the direct costs of stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Dec. 2003;14(6):403-11. Not eligible outcomes. [pmid: 14677002].
1864 King L, Pilcher M. A multidisciplinary approach to improving urinary continence. Nurs Stand. Oct 29–Nov 4. 2008;23(8):42-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18986080].
1865 Kinn AC. Tension-free vaginal tape evaluated using patient self-reports and urodynamic testing--a two-year follow-up. Scand J Urol Nephrol. Dec. 2001;35(6):484-90. Not eligible exposure. [pmid: 11848428].
1866 Kinn AC, Larsson PO. Desmopressin: a new principle for symptomatic treatment of urgency and incontinence in patients with multiple sclerosis. Scand J Urol Nephrol. 1990;24(2):109-12. Not eligible target population. [pmid: 2192444].
1867 Kinn AC, Zaar A. Quality of life and urinary incontinence pad use in women. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(2):83-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9694136].
1868 Kirby M. A review of the role of primary care in the diagnosis and management of stress urinary incontinence. Health Serv J. Sep. 16. 2004;114(5923). suppl 3–7. following 54. review. [pmid: 15503907].
1869 Kirkham AP, Knight SL, Craggs MD, et al. Neuromodulation through sacral nerve roots 2 to 4 with a Finetech-Brindley sacral posterior and anterior root stimulator. Spinal Cord. Jun. 2002;40(6):272-81. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12037708].
1870 Kirkland VL, Palmer MH, Fitzgerald ST. Incontinence in a manufacturing setting: women’s perceptions and responses. Public Health Nurs. Sep–Oct. 2001;18(5):312-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11559414].
1871 Kirschner-Hermanns R, Kemp B, Maass N, et al. Functional Pelvic Floor Magnetic Stimulation in the Treatment of Urinary Incontinence, Pelvic Pain Symptoms and Stool Smearing. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep –3 Oct 2009. Not eligible case series.
1872 Kitamura H, Miyao N, Yanase M, et al. Quality of life in patients having an ileal conduit, continent reservoir or orthotopic neobladder after cystectomy for bladder carcinoma. Int J Urol. Aug. 1999;6(8):393-9. Not eligible exposure. [pmid: 10466451].
1873 Kitchener HC, Dunn G, Lawton V, et al. Laparoscopic versus open colposuspension--results of a prospective randomised controlled trial. BJOG : an international journal of obstetrics and gynaecology. 2006:1007-13. Not eligible exposure. [pmid: 16956332].
1874 Kjerulff KH, Langenberg PW, Greenaway L, et al. Urinary incontinence and hysterectomy in a large prospective cohort study in American women. J Urol. May. 2002;167(5):2088-92. Not eligible target population. [pmid: 11956446].
1875 Kjerulff KH, Langenberg PW, Rhodes JC, et al. Effectiveness of hysterectomy. Obstet Gynecol. Mar. 2000;95(3):319-26. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10711536].
1876 Kjolhede P. Long-term efficacy of Burch colposuspension: a 14-year follow-up study. Acta Obstet Gynecol Scand. Aug. 2005;84(8):767-72. Not eligible exposure. [pmid: 16026403].
1877 Kjolhede P, Wahlstrom J, Wingren G. Pelvic floor dysfunction after Burch colposuspension--a comprehensive study. Part I. Acta Obstet Gynecol Scand. Sep. 2005;84(9):894-901. Not eligible exposure. [pmid: 16097983].
1878 Klausner TI. Make your practice distinct. Adv Nurse Pract. Oct. 2005;13(10):15. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16231546].
1879 Klay M, Marfyak K. Use of a continence nurse specialist in an extended care facility. Urol Nurs. Apr. 2005;25(2):101-2. 7. 8. Not eligible target population. [pmid: 15900978].
1880 Klein MC, Gauthier RJ, Jorgensen SH, et al. Does episiotomy prevent perineal trauma and pelvic floor relaxation?. Online J Curr Clin Trials. 1992. Jul. 1. Doc No 10:[6019 words; 65 paragraphs]. Not eligible exposure. [pmid: 1343606].
1881 Klotz R, Joseph PA, Ravaud JF, et al. The Tetrafigap Survey on the long-term outcome of tetraplegic spinal cord injured persons: Part III. Medical complications and associated factors. Spinal Cord. Sep. 2002;40(9):457-67. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12185607].
1882 Kluivers KB, Mol BW, Bremer GL, et al. Pelvic organ function in randomized patients undergoing laparoscopic or abdominal hysterectomy. J Minim Invasive Gynecol. Jul–Aug. 2007;14(4):442-8. Not eligible exposure. [pmid: 17630161].
1883 Kneist W, Junginger T. Long-term urinary dysfunction after mesorectal excision: a prospective study with intraoperative electrophysiological confirmation of nerve preservation. Eur J Surg Oncol. Nov. 2007;33(9):1068-74. Not eligible target population. [pmid: 17524598].
1884 Knight J. Positive thinking. Nurs Stand. Feb. 16–22. 2000;14(22):18-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11310030].
1885 Ko Y, Lin SJ, Salmon JW, et al. The impact of urinary incontinence on quality of life of the elderly. Am J Manag Care. Jul. 2005;11(4 Suppl):S103-11. Not eligible exposure. [pmid: 16161383].
1886 Kobak W, Lu J, Hardart A, et al. Expression of lysyl oxidase and transforming growth factor beta2 in women with severe pelvic organ prolapse. J Reprod Med. Nov. 2005;50(11):827-31. Not eligible exposure. [pmid: 16419630].
1887 Kobata SA, Girao MJ, Baracat EC, et al. Estrogen therapy influence on periurethral vessels in postmenopausal incontinent women using Dopplervelocimetry analysis. Maturitas. Nov. 20. 2008;61(3):243-7. Not eligible outcomes. [pmid: 18845407].
1888 Kobelt G. Economic considerations and outcome measurement in urge incontinence. Urology. Dec. 1997;50(6A Suppl):100-7. discussion 8–10. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9426762].
1889 Kobelt G, Fianu-Jonasson A. Treatment of stress urinary incontinence with non-animal stabilised hyaluronic acid/dextranomer (NASHA/Dx) gel : An analysis of utility and cost. Clin Drug Investig. 2006;26(10):583-91. Not eligible outcomes. [pmid: 17163292].
1890 Kocak I, Okyay P, Dundar M, et al. Female urinary incontinence in the west of Turkey: prevalence, risk factors and impact on quality of life. Eur Urol. Oct. 2005;48(4):634-41. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15963633].
1891 Koch MO, Nayee AH, Sloan J, et al. Early catheter removal after radical retropubic prostatectomy: long-term followup. J Urol. Jun. 2003;169(6):2170-2. Not eligible target population. [pmid: 12771741].
1892 Koch T, Kelly S. Understanding what is important for women who live with multiple sclerosis. Aust J Holist Nurs. Apr. 1999;6(1):14-24. Not eligible target population. [pmid: 11898197].
1893 Koch T, Kelly S. Identifying strategies for managing urinary incontinence with women who have multiple sclerosis. J Clin Nurs. Sep. 1999;8(5):550-9. Not eligible target population. [pmid: 10786527].
1894 Koch T, Kralik D, Eastwood S, et al. Breaking the silence: women living with multiple sclerosis and urinary incontinence. Int J Nurs Pract. Feb. 2001;7(1):16-23. Not eligible target population. [pmid: 11811342].
1895 Kochakarn W. Tension-free vaginal tape procedure for the treatment of stress urinary incontinence: the first experience in Thailand. J Med Assoc Thai. Jan. 2002;85(1):87-91. Not eligible exposure. [pmid: 12075727].
1896 Kocjancic E, Crivellaro S, Oyama IA, et al. Transobturator tape in the management of female stress incontinence: clinical outcomes at medium term follow-up. Urol Int. 2008;80(3):275-8. Not eligible exposure. [pmid: 18480630].
1897 Kocjancic E, Crivellaro S, Ranzoni S, et al. Adjustable Continence Therapy for the treatment of male stress urinary incontinence: a single-centre study. Scand J Urol Nephrol. 2007;41(4):324-8. Not eligible target population. [pmid: 17763225].
1898 Kocjancic E, Hubner W, Trigo Rocha F, et al. International multi-centre evaluation of the adjustable continence therapy (proact(TM(TM)) for male post prostatectomy stress urinary incontinence. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Not eligible target population.
1899 Kohler-Ockmore J, Feneley RC. Long-term catheterization of the bladder: prevalence and morbidity. Br J Urol. Mar. 1996;77(3):347-51. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8814836].
1900 Komorowski L, Chen B. Female urinary incontinence in China: experiences and perspectives. Health Care Women Int. Feb. 2006;27(2):169-81. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16484160].
1901 Kondo A, Isobe Y, Kimura K, et al. Efficacy, safety and hospital costs of tension-free vaginal tape and pubovaginal sling in the surgical treatment of stress incontinence. J Obstet Gynaecol Res. Dec. 2006;32(6):539-44. Not eligible exposure. [pmid: 17100814].
1902 Kondo A, Yamada Y, Niijima R. Treatment of stress incontinence by vaginal cones: short- and long-term results and predictive parameters. Br J Urol. Oct. 1995;76(4):464-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7551882].
1903 Kondo A, Yokoyama E, Koshiba K, et al. Bladder neck support prosthesis: a nonoperative treatment for stress or mixed urinary incontinence. J Urol. Mar. 1997;157(3):824-7. Not eligible target population. [pmid: 9072577].
1904 Koonings PP, Bergman A, Ballard CA. Prostaglandins for enhancing detrusor function after surgery for stress incontinence in women. J Reprod Med. Jan. 1990;35(1):1-5. Not eligible exposure. [pmid: 2299605].
1905 Korfage IJ, de Koning HJ, Habbema JD, et al. Side-effects of treatment for localized prostate cancer: are they valued differently by patients and healthy controls?. BJU Int. Apr. 2007;99(4):801-6. Not eligible target population. [pmid: 17233804].
1906 Korman HJ, Sirls LT, Kirkemo AK. Success rate of modified Pereyra bladder neck suspension determined by outcomes analysis. J Urol. Nov. 1994;152(5 Pt 1):1453-7. Not eligible exposure. [pmid: 7933182].
1907 Korn AP, Learman LA. Operations for stress urinary incontinence in the United States, 1988–1992. Urology. Oct. 1996;48(4):609-12. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8886068].
1908 Kowalczyk JJ. Office evaluation of the patient with an overactive urinary bladder. J Am Osteopath Assoc. Mar. 2000;100(3 Suppl):S1-4. no primary result. [pmid: 10763310].
1909 Koyama W, Koyanagi A, Mihara S, et al. Prevalence and conditions of urinary incontinence among the elderly. Methods Inf Med. Jun. 1998;37(2):151-5. Not eligible target population. [pmid: 9656656].
1910 Krahn M, Ritvo P, Irvine J, et al. Patient and community preferences for outcomes in prostate cancer: implications for clinical policy. Med Care. Jan. 2003;41(1):153-64. Not eligible target population. [pmid: 12544552].
1911 Kralj B. Conservative treatment of female stress urinary incontinence with functional electrical stimulation. European Journal of Obstetrics Gynecology and Reproductive Biology. 1999;85(1):53-6. Level of evidence.
1912 Kramer SA, Rathbun SR, Elkins D, et al. Double-blind placebo controlled study of alpha-adrenergic receptor antagonists (doxazosin) for treatment of voiding dysfunction in the pediatric population. J Urol. Jun. 2005;173(6):2121-4. discussion 4. Not eligible target population. [pmid: 15879863].
1913 Kraus SR, Markland A, Chai TC, et al. Race and ethnicity do not contribute to differences in preoperative urinary incontinence severity or symptom bother in women who undergo stress incontinence surgery. Am J Obstet Gynecol. Jul. 2007;197(1):92 e1-6. Not eligible outcomes. [pmid: 17618773].
1914 Krause C, Wells T, Hughes S, et al. Incontinence in women: effect of expectancy to regain control and severity of symptoms on treatment outcomes. Urol Nurs. Feb. 2003;23(1):54-61. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12677720].
1915 Krauwinkel WJ, Smulders RA, Mulder H, et al. Effect of age on the pharmacokinetics of solifenacin in men and women. Int J Clin Pharmacol Ther. May. 2005;43(5):227-38. Not eligible outcomes. [pmid: 15906588].
1916 Kreder K. Long-term safety, tolerability, and efficacy of extended-release tolterodine in the treatment of overactive bladder: a review and update. review.
1917 Kristiansson P, Samuelsson E, von Schoultz B, et al. Reproductive hormones and stress urinary incontinence in pregnancy. Acta Obstet Gynecol Scand. Dec. 2001;80(12):1125-30. Not eligible target population. [pmid: 11846710].
1918 Krofta L, Feyereisl J, Otcenasek M, et al. TVT and TVT-O for surgical treatment of primary stress urinary incontinence: prospective randomized trial. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2010;21(2):141-8. Not eligible exposure. [pmid: 19907913].
1919 Krogh K, Christensen P, Sabroe S, et al. Neurogenic bowel dysfunction score. Spinal Cord. Oct. 2006;44(10):625-31. Not eligible target population. [pmid: 16344850].
1920 Krupski TL, Saigal CS, Litwin MS. Variation in continence and potency by definition. J Urol. Oct. 2003;170(4 Pt 1):1291-4. Not eligible target population. [pmid: 14501744].
1921 Ku JH, Jeong IG, Lim DJ, et al. Voiding diary for the evaluation of urinary incontinence and lower urinary tract symptoms: prospective assessment of patient compliance and burden. Neurourol Urodyn. 2004;23(4):331-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15227650].
1922 Kubik K, Blackwell L, Heit M. Does socioeconomic status explain racial differences in urinary incontinence knowledge?. Am J Obstet Gynecol. Jul. 2004;191(1):188-93. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15295363].
1923 Kubler HR, Tseng TY, Sun L, et al. Impact of nerve sparing technique on patient self-assessed outcomes after radical perineal prostatectomy. J Urol. Aug. 2007;178(2):488-92. discussion 92. Not eligible target population. [pmid: 17561133].
1924 Kuczyk MA, Klein S, Grunewald V, et al. A questionnaire-based outcome analysis of the Stamey bladder neck suspension procedure for the treatment of urinary stress incontinence: the Hannover experience. Br J Urol. Aug. 1998;82(2):174-80. Not eligible exposure. [pmid: 9722750].
1925 Kuhn A, Stadlmayr W, Lengsfeld D, et al. Where should bulking agents for female urodynamic stress incontinence be injected?. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2008;19(6):817-21. Not eligible exposure. [pmid: 18157642].
1926 Kuhn A, Stadlmayr W, Sohail A, et al. Long-term results and patients’ satisfaction after transurethral ethylene vinyl alcohol (Tegress) injections: a two-centre study. Int Urogynecol J Pelvic Floor Dysfunct. Apr. 2008;19(4):503-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17955152].
1927 Kuhn A, Vits K, Kuhn P, et al. Do women with urinary incontinence really know where all the toilets are? The toilet paper. Eur J Obstet Gynecol Reprod Biol. Nov. 2006;129(1):65-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16337072].
1928 Kuhn W, Rist M, Zaech GA. Intermittent urethral self-catheterisation: long term results (bacteriological evolution, continence, acceptance, complications). Paraplegia. May. 1991;29(4):222-32. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 1870888].
1929 Kulseng-Hanssen S. The development of a national database of the results of surgery for urinary incontinence in women. BJOG. Nov. 2003;110(11):975-82. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14592581].
1930 Kulseng-Hanssen S, Husby H, Schiotz HA. The tension free vaginal tape operation for women with mixed incontinence: Do preoperative variables predict the outcome?. Neurourol Urodyn. 2007;26(1):115-21. discussion 22. Not eligible exposure. [pmid: 16894616].
1931 Kumar A, Litt ER, Ballert KN, et al. Artificial urinary sphincter versus male sling for post-prostatectomy incontinence--what do patients choose?. J Urol. Mar. 2009;181(3):1231-5. Not eligible target population. [pmid: 19152937].
1932 Kumar H, Cauchi J, MacKinnon AE. Periurethral Goretex sling in lower urinary reconstruction. Eur J Pediatr Surg. Dec. 1999;9(Suppl 1):33-4. Not eligible exposure. [pmid: 10661790].
1933 Kumar V, Toussi H, Marr C, et al. The benefits of radical prostatectomy beyond cancer control in symptomatic men with prostate cancer. BJU Int. Mar. 2004;93(4):507-9. Not eligible target population. [pmid: 15008719].
1934 Kung RC, Lie K, Lee P, et al. The cost-effectiveness of laparoscopic versus abdominal Burch procedures in women with urinary stress incontinence. J Am Assoc Gynecol Laparosc. Aug. 1996;3(4):537-44. Not eligible exposure. [pmid: 9050685].
1935 Kunkel EJ, Myers RE, Lartey PL, et al. Communicating effectively with the patient and family about treatment options for prostate cancer. Semin Urol Oncol. Aug. 2000;18(3):233-40. Not eligible target population. [pmid: 10975496].
1936 Kuo HC. Clinical outcome and quality of life after enterocystoplasty for contracted bladders. Urol Int. 1997;58(3):160-5. Not eligible target population. [pmid: 9188137].
1937 Kuo HC. Quality of life after active urological management of chronic spinal cord injury in eastern Taiwan. Eur Urol. 1998;34(1):37-46. Not eligible target population. [pmid: 9676412].
1938 Kuo HC. Comparison of video urodynamic results after the pubovaginal sling procedure using rectus fascia and polypropylene mesh for stress urinary incontinence. J Urol. Jan. 2001;165(1):163-8. Not eligible exposure. [pmid: 11125388].
1939 Kuo HC. Long-term results of surgical treatment for female stress urinary incontinence. Urol Int. 2001;66(1):13-7. Not eligible exposure. [pmid: 11150944].
1940 Kuo HC. Anatomical and functional results of pubovaginal sling procedure using polypropylene mesh for the treatment of stress urinary incontinence. J Urol. Jul. 2001;166(1):152-7. Not eligible exposure. [pmid: 11435845].
1941 Kuo HC. The surgical results of the pubovaginal sling procedure using polypropylene mesh for stress urinary incontinence. BJU Int. Dec. 2001;88(9):884-8. Not eligible exposure. [pmid: 11851608].
1942 Kuo HC. Urodynamic evidence of effectiveness of botulinum A toxin injection in treatment of detrusor overactivity refractory to anticholinergic agents. Urology. May. 2004;63(5):868-72. Not eligible target population. [pmid: 15134967].
1943 Kuo HC. Multiple intravesical instillation of low-dose resiniferatoxin is effective in the treatment of detrusor overactivity refractory to anticholinergics. BJU Int. May. 2005;95(7):1023-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15839924].
1944 Kuo HC. Effectiveness of urethral injection of botulinum A toxin in the treatment of voiding dysfunction after radical hysterectomy. Urol Int. 2005;75(3):247-51. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16215314].
1945 Kuo HC. Will suburothelial injection of small dose of botulinum A toxin have similar therapeutic effects and less adverse events for refractory detrusor overactivity?. Urology. Nov. 2006;68(5):993-7. discussion 7–8. Not eligible target population. [pmid: 17113890].
1946 Kuo HC. Therapeutic satisfaction and dissatisfaction in patients with spinal cord lesions and detrusor sphincter dyssynergia who received detrusor botulinum toxin a injection. Urology. Nov. 2008;72(5):1056-60. Not eligible target population. [pmid: 18533231].
1947 Kuo HC. Satisfaction with urethral injection of botulinum toxin A for detrusor sphincter dyssynergia in patients with spinal cord lesion. Neurourology & Urodynamics. 2008;27(8):793-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18508331].
1948 Kuo HC, Liu HT, Yang WC. Therapeutic effect of multiple resiniferatoxin intravesical instillations in patients with refractory detrusor overactivity: a randomized, double-blind, placebo controlled study. J Urol. Aug. 2006;176(2):641-5. Not eligible exposure. [pmid: 16813911].
1949 Kurfuerst S. Stop before it starts. Rehab Manag. Oct. 2003;16(8):42-4. 54. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14558425].
1950 Kursh ED. Factors influencing the outcome of a no incision endoscopic urethropexy. Surg Gynecol Obstet. Sep. 1992;175(3):254-8. Not eligible exposure. [pmid: 1514161].
1951 Kuschel S, Schuessler B. Results on function and safety of the Safyre-t, a hybrid transobturator vaginal sling for the treatment of stress urinary incontinence. Neurourol Urodyn. 2008;27(5):403-6. Not eligible exposure. [pmid: 17985372].
1952 Kuznetsov DD, Kim HL, Patel RV, et al. Comparison of artificial urinary sphincter and collagen for the treatment of postprostatectomy incontinence. Urology. Oct. 1. 2000;56(4):600-3. Not eligible target population. [pmid: 11018614].
1953 Kwon E, Schulz JA, Flood CG. Success of pubovaginal sling in patients with stress urinary incontinence and efficacy of vaginal sling release in patients with post-sling voiding dysfunction. J Obstet Gynaecol Can. Jun. 2006;28(6):519-25. Not eligible exposure. [pmid: 16857120].
1954 Labrie J, van der Graaf Y, Buskens E, et al. Protocol for Physiotherapy Or TVT Randomised Efficacy Trial (PORTRET): a multicentre randomised controlled trial to assess the cost-effectiveness of the tension free vaginal tape versus pelvic floor muscle training in women with symptomatic moderate to severe stress urinary incontinence. BMC Womens Health. 2009;9:24. Not eligible exposure. [pmid: 19723313].
1955 Lachowsky M. Urinary problems around the menopause; emotional and psychological consequences; can we help our patients to cope with them?. Maturitas. Jan. 2000;34(Suppl 1):S25-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10759061].
1956 Ladwig D, Miljkovic-Petkovic L, Hewson AD. Simplified colposuspension: a 15-year follow-up. Aust N Z J Obstet Gynaecol. Feb. 2004;44(1):39-45. Not eligible exposure. [pmid: 15089867].
1957 Lagergren M, Fratiglioni L, Hallberg IR, et al. A longitudinal study integrating population, care and social services data. The Swedish National study on Aging and Care (SNAC). Aging Clin Exp Res. Apr. 2004;16(2):158-68. Not eligible target population. [pmid: 15195992].
1958 Lagro-Janssen T, van Weel C. Long-term effect of treatment of female incontinence in general practice. Br J Gen Pract. Nov. 1998;48(436):1735-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10198479].
1959 Lai HH, Hsu EI, Teh BS, et al. 13 years of experience with artificial urinary sphincter implantation at Baylor College of Medicine. Journal of Urology. Mar. 2007;177(3):1021-5. Not eligible target population. [pmid: 17296403].
1960 Lajiness MJ, Wolfert C, Hall S, et al. Group session teaching of behavioral modification program for urinary incontinence: establishing the teachers. Urol Nurs. Apr. 2007;27(2):124-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17494451].
1961 Lakeman M, Kruitwagen RF, Vos MC, et al. Electrosurgical bipolar vessel sealing versus conventional clamping and suturing for total abdominal hysterectomy: a randomized trial. J Minim Invasive Gynecol. Sep–Oct. 2008;15(5):547-53. Not eligible target population. [pmid: 18619923].
1962 Lal M, Pattison HM, Allan TF, et al. Postcesarean pelvic floor dysfunction contributes to undisclosed psychosocial morbidity. J Reprod Med. Feb. 2009;54(2):53-60. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 19301567].
1963 Lal R, Bhatnagar V, Agarwala S, et al. Urodynamic evaluation in boys treated for posterior urethral valves. Pediatr Surg Int. Jul. 1999;15(5–6):358-62. Not eligible exposure. [pmid: 10415286].
1964 Lal R, Bhatnagar V, Mitra DK. Urinary continence following posterior urethral valves treatment. Indian J Pediatr. Jan–Feb. 1999;66(1):49-54. Not eligible exposure. [pmid: 10798036].
1965 Lalos O, Berglund AL, Bjerle P. Urodynamics in women with stress incontinence before and after surgery. Eur J Obstet Gynecol Reprod Biol. Mar. 1993;48(3):197-205. Not eligible exposure. [pmid: 8335138].
1966 Lalos O, Berglund AL, Lalos A. Impact of urinary and climacteric symptoms on social and sexual life after surgical treatment of stress urinary incontinence in women: a long-term outcome. J Adv Nurs. Feb. 2001;33(3):316-27. Not eligible exposure. [pmid: 11251718].
1967 Lamers BH, van der Vaart CH. Medium-term efficacy of pelvic floor muscle training for female urinary incontinence in daily practice. Int Urogynecol J Pelvic Floor Dysfunct. Mar. 2007;18(3):301-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16791704].
1968 Land R, Parry E, Rane A, et al. Personal preferences of obstetricians towards childbirth. Aust N Z J Obstet Gynaecol. Aug. 2001;41(3):249-52. Not eligible exposure. [pmid: 11592537].
1969 Landrum BJ. Marketing innovations to nurses, Part 2: Marketing’s role in the adoption of innovations. J Wound Ostomy Continence Nurs. Sep. 1998;25(5):227-32. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9923256].
1970 Lang JH, Zhu L, Sun ZJ, et al. Estrogen levels and estrogen receptors in patients with stress urinary incontinence and pelvic organ prolapse. Int J Gynaecol Obstet. Jan. 2003;80(1):35-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12527458].
1971 Langa KM, Fultz NH, Saint S, et al. Informal caregiving time and costs for urinary incontinence in older individuals in the United States. J Am Geriatr Soc. Apr. 2002;50(4):733-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11982676].
1972 Langer R, Golan A, Arad D, et al. Effects of induced menopause on Burch colposuspension for urinary stress incontinence. J Reprod Med. Dec. 1992;37(12):956-8. Not eligible exposure. [pmid: 1287204].
1973 Langford CF, Elmissiry MM, Ghoniem GM. Do women have realistic expectations of treatment for stress urinary incontinence?. Neurourol Urodyn. 2008;27(6):480-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18551570].
1974 Langley T. Training staff to provide a continence helpline. Prof Nurse. Nov. 1995;11(2):121-4. Not eligible target population. [pmid: 7480053].
1975 Lantz RJ, Gillespie TA, Rash TJ, et al. Metabolism, excretion, and pharmacokinetics of duloxetine in healthy human subjects. Drug Metab Dispos. Sep. 2003;31(9):1142-50. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12920170].
1976 Lapitan MC, Cody DJ, Grant AM. Open retropubic colposuspension for urinary incontinence in women. Cochrane Database Syst Rev. 2005;(3):CD002912. Not elgible exposure. [pmid: 16034879].
1977 Lara C, Nacey J. Ethnic differences between Maori, Pacific Island and European New Zealand women in prevalence and attitudes to urinary incontinence. N Z Med J. Sep. 28. 1994;107(986 Pt 1):374-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7619104].
1978 Larson B, Collins A, Landgren BM. Urogenital and vasomotor symptoms in relation to menopausal status and the use of hormone replacement therapy (HRT) in healthy women during transition to menopause. Maturitas. Dec. 15. 1997;28(2):99-105. Not eligible target population. [pmid: 9522318].
1979 LaSala CA, Kuchel GA. Evaluation and management of urinary incontinence in elderly women. Conn Med. Sep. 2003;67(8):491-5. no primary result. [pmid: 14587130].
1980 Lassmann J, Garibay Gonzalez F, Melchionni JB, et al. Sexual function in adult patients with spina bifida and its impact on quality of life. J Urol. Oct. 2007;178(4 Pt 2):1611-4. Not eligible target population. [pmid: 17707040].
1981 Latini JM, Alipour M, Kreder KJ Jr. Efficacy of sacral neuromodulation for symptomatic treatment of refractory urinary urge incontinence. Urology. Mar. 2006;67(3):550-3. discussion 3–4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16527577].
1982 Latini JM, Brown JA, Kreder KJ. Abdominal sacral colpopexy using autologous fascia lata. J Urol. Mar. 2004;171(3):1176-9. Not eligible exposure. [pmid: 14767295].
1983 Latini JM, Lux MM, Kreder KJ. Efficacy and morbidity of autologous fascia lata sling cystourethropexy. J Urol. Mar. 2004;171(3):1180-4. Not eligible exposure. [pmid: 14767296].
1984 Latthe PM, Patodi M, Constantine G. Transobturator tape procedure in stress urinary incontinence: UK experience of a district general hospital. Journal of Obstetrics & Gynaecology. Feb. 2007;27(2):177-80. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17454470].
1985 Laubach J. The problem of urinary incontinence in the elderly. N C Med J. Jan–Feb. 1999;60(1):42-5. Comment. [pmid: 9951288].
1986 Laurikainen E, Valpas A, Kivelä A, et al. Retropubic compared with transobturator tape placement in treatment of urinary incontinence: a randomized controlled trial. Obstetrics and gynecology. 2007:4-11. Not eligible exposure. [pmid: 17197581].
1987 Laurikkala J, Juhola M, Lammi S, et al. Analysis of the imputed female urinary incontinence data for the evaluation of expert system parameters. Comput Biol Med. Jul. 2001;31(4):239-57. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11334634].
1988 Lauti M, Herbison P, Hay-Smith J, et al. Anticholinergic drugs, bladder retraining and their combination for urge urinary incontinence: a pilot randomised trial. International Urogynecology Journal. Nov. 2008;19(11):1533-43. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 21526].
1989 Lawhorne LW, Ouslander JG, Parmelee PA, et al. Urinary incontinence: a neglected geriatric syndrome in nursing facilities. J Am Med Dir Assoc. Jan. 2008;9(1):29-35. Not eligible target population. [pmid: 18187110].
1990 Lawrence JM, Lukacz ES, Liu IL, et al. Pelvic floor disorders, diabetes, and obesity in women: findings from the Kaiser Permanente Continence Associated Risk Epidemiology Study. Diabetes Care. Oct. 2007;30(10):2536-41. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17620443].
1991 Layward L, Holmes P. Research to combat urinary incontinence. Br J Community Nurs. Oct. 2006;11(10):433-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17167357].
1992 Lazzeri M, Calo G, Spinelli M, et al. Urodynamic effects of intravesical nociceptin/orphanin FQ in neurogenic detrusor overactivity: a randomized, placebo-controlled, double-blind study. Urology. May. 2003;61(5):946-50. Not eligible target population. [pmid: 12736013].
1993 Leach GE. Local anesthesia for urologic procedures. Urology. Aug. 1996;48(2):284-8. Not eligible target population. [pmid: 8753742].
1994 Leandri P, Rossignol G, Gautier JR, et al. Radical retropubic prostatectomy: morbidity and quality of life. Experience with 620 consecutive cases. J Urol. Mar. 1992;147(3 Pt 2):883-7. Not eligible target population. [pmid: 1538489].
1995 Learman LA, Summitt RL Jr, Varner RE, et al. A randomized comparison of total or supracervical hysterectomy: surgical complications and clinical outcomes. Obstet Gynecol. Sep. 2003;102(3):453-62. Not eligible target population. [pmid: 12962924].
1996 Lebret T, Botto H, Benchetrit J, et al. Results of the French Multicentric Prospective Study for Treatment of Stress Urinary Incontinence with Proact Balloons after Prostate Surgery. Paper presented at: 2006 Annual Meeting of the American Urological Association (AUA 2006). Atlanta, Georgia (USA). 20–25 May 2006. Not eligible target population.
1997 Lebret T, Cour F, Benchetrit J, et al. Treatment of postprostatectomy stress urinary incontinence using a minimally invasive adjustable continence balloon device, ProACT: results of a preliminary, multicenter, pilot study. Urology. Feb. 2008;71(2):256-60. Not eligible target population. [pmid: 18308096].
1998 Lee CL, Yen CF, Wang CJ, et al. Extraperitoneal approach to laparoscopic Burch colposuspension. J Am Assoc Gynecol Laparosc. Aug. 2001;8(3):374-7. Not eligible exposure. [pmid: 11509776].
1999 Lee CL, Yen CF, Wang CJ, et al. Trocar-assisted sling suspension for stress urinary incontinence. J Am Assoc Gynecol Laparosc. Nov. 2002;9(4):500-2. Not elgible exposure. [pmid: 12386363].
2000 Lee CT, Sandler HM, Kim KM, et al. Conformational radiation therapy after radical prostatectomy: Effect of urinary incontinence. Paper presented at: 82nd Scientific Assembly and Annual Meeting of the Radiological Society of North America. Chicago, IL (USA). 1–6 Dec 1996. (World Meeting Number 964 0124). Not eligible target population.
2001 Lee E, Yoo KY, Kim Y, et al. Prevalence of lower urinary tract symptoms in Korean men in a community-based study. Eur Urol. 1998;33(1):17-21. Not eligible target population. [pmid: 9471036].
2002 Lee IS, Choi ES. Pelvic floor muscle exercise by biofeedback and electrical stimulation to reinforce the pelvic floor muscle after normal delivery. Taehan Kanho Hakhoe Chi. 2006:1374-80. Not eligible target population. [pmid: 17215611].
2003 Lee JH, Kim KH, Lee HW, et al. Distal urethral polypropylene sling surgical management for urodynamic stress incontinence in Korean women. Urol Int. 2009;82(2):191-5. Not eligible exposure. [pmid: 19322009].
2004 Lee JY, Kim HW, Lee SJ, et al. Comparison of doxazosin with or without tolterodine in men with symptomatic bladder outlet obstruction and an overactive bladder. BJU Int. Oct. 2004;94(6):817-20. Not eligible target population. [pmid: 15476515].
2005 Lee KS, Choo MS, Doo CK, et al. The long term (5-years) objective TVT success rate does not depend on predictive factors at multivariate analysis: a multicentre retrospective study. Eur Urol. Jan. 2008;53(1):176-82. Not eligible exposure. [pmid: 17825478].
2006 Lee KS, Choo MS, Kim DY, et al. Combination treatment with propiverine hydrochloride plus doxazosin controlled release gastrointestinal therapeutic system formulation for overactive bladder and coexisting benign prostatic obstruction: a prospective, randomized, controlled multicenter study. J Urol. Oct. 2005;174(4 Pt 1):1334-8. Not eligible target population. [pmid: 16145414].
2007 Lee KS, Choo MS, Lee YS, et al. Prospective comparison of the ‘inside-out’ and ‘outside-in’ transobturator-tape procedures for the treatment of female stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Apr. 2008;19(4):577-82. Not eligible exposure. [pmid: 17940717].
2008 Lee KS, Han DH, Choi YS, et al. A prospective trial comparing tension-free vaginal tape and transobturator vaginal tape inside-out for the surgical treatment of female stress urinary incontinence: 1-year followup. J Urol. Jan. 2007;177(1):214-8. Not eligible exposure. [pmid: 17162048].
2009 Lee KS, Sung HH, Na S, et al. Prevalence of urinary incontinence in Korean women: results of a National Health Interview Survey. World J Urol. Apr. 2008;26(2):179-85. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18265989].
2010 Lee YJ, Chiang YF, Tsai JC. Severe nonproductive cough and cough-induced stress urinary incontinence in diabetic postmenopausal women treated with ACE inhibitor. Diabetes Care. Mar. 2000;23(3):427-8. Not eligible target population. [pmid: 10868884].
2011 Lehtonen T. The Effect of Phenylpropanolamine on female stress urinary incontinence. Annales chirurgiae et gynaecologiae. 1986;75:236-41. Not eligible exposure. [pmid: 3535621].
2012 Leibovich BC, Barrett DM. Use of the artificial urinary sphincter in men and women. World J Urol. 1997;15(5):316-9. Not eligible target population. [pmid: 9372584].
2013 Leiby DM, Shanahan N. Clinical study: assessing the performance and skin environments of two reusable underpads. Ostomy Wound Manage. Oct. 1994;40(8):30-2. 4. 7. Not eligible target population. [pmid: 7546098].
2014 Lekan-Rutledge D. Behavioral vs drug treatment for urge urinary incontinence in older women: a randomized controlled trial. J Wound Ostomy Continence Nurs. May. 1999;26(3):27A-8A. Comment. [pmid: 10711115].
2015 Lekan-Rutledge D. Diffusion of innovation. A model for implementation of prompted voiding in long-term care settings. J Gerontol Nurs. Apr. 2000;26(4):25-33. Not eligible target population. [pmid: 11272963].
2016 Lekan-Rutledge D, Palmer MH, Belyea M. In their own words: nursing assistants’ perceptions of barriers to implementation of prompted voiding in long-term care. Gerontologist. Jun. 1998;38(3):370-8. Not eligible target population. [pmid: 9640857].
2017 Lekka E, Lee LK. Successful treatment with intradetrusor Botulinum-A toxin for urethral urinary leakage (catheter bypassing) in patients with end-staged multiple sclerosis and indwelling suprapubic catheters. Eur Urol. Oct. 2006;50(4):806-9. discussion 9–10. Not eligible target population. [pmid: 16413661].
2018 Lemack GE, Krauss S, Litman H, et al. Normal preoperative urodynamic testing does not predict voiding dysfunction after Burch colposuspension versus pubovaginal sling. J Urol. Nov. 2008;180(5):2076-80. Not eligible exposure. [pmid: 18804239].
2019 Lemack GE, Xu Y, Brubaker L, et al. Clinical and demographic factors associated with valsalva leak point pressure among women undergoing burch bladder neck suspension or autologous rectus fascial sling procedures. Neurourol Urodyn. 2007;26(3):392-6. Not eligible exposure. [pmid: 17304525].
2020 Lemack GE, Zimmern PE. Sexual function after vaginal surgery for stress incontinence: results of a mailed questionnaire. Urology. Aug. 1. 2000;56(2):223-7. Not eligible exposure. [pmid: 10925082].
2021 Lemelle JL, Guillemin F, Aubert D, et al. Quality of life and continence in patients with spina bifida. Qual Life Res. Nov. 2006;15(9):1481-92. Not eligible target population. [pmid: 17033913].
2022 Lenihan JP. Comparison of the quality of life after nonsurgical radiofrequency energy tissue micro-remodeling in premenopausal and postmenopausal women with moderate-to-severe stress urinary incontinence. Am J Obstet Gynecol. Jun. 2005;192(6):1995-8. discussion 9–2001. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15970873].
2023 Lepire E, Hatem M. Adaptation and use of health services by primiparous women with urinary incontinence. J Obstet Gynecol Neonatal Nurs. May–Jun. 2007;36(3):222-30. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17489928].
2024 Lepisto M, Eriksson E, Hietanen H, et al. Developing a pressure ulcer risk assessment scale for patients in long-term care. Ostomy Wound Manage. Feb. 2006;52(2):34-46. Not eligible target population. [pmid: 16464993].
2025 Lepor H, Theune C. Randomized double-blind study comparing the efficacy of terazosin versus placebo in women with prostatism-like symptoms. J Urol. Jul. 1995;154(1):116-8. Not eligible exposure. [pmid: 7776406].
2026 Lerner SE, Fleischmann J, Taub HC, et al. Combined laparoscopic pelvic lymph node dissection and modified belt radical perineal prostatectomy for localized prostatic adenocarcinoma. Urology. Apr. 1994;43(4):493-8. Not eligible target population. [pmid: 8154070].
2027 Letourneau R, Pang X, Sant GR, et al. Intragranular activation of bladder mast cells and their association with nerve processes in interstitial cystitis. Br J Urol. Jan. 1996;77(1):41-54. Not eligible target population. [pmid: 8653316].
2028 Levinson AW, Bagga HS, Pavlovich CP, et al. The impact of prostate size on urinary quality of life indexes following laparoscopic radical prostatectomy. J Urol. May. 2008;179(5):1818-22. Not eligible target population. [pmid: 18353375].
2029 Levitt MA, Pena A. Outcomes from the correction of anorectal malformations. Curr Opin Pediatr. Jun. 2005;17(3):394-401. Not eligible target population. [pmid: 15891433].
2030 Levy-Storms L, Schnelle JF, Simmons SF. What do family members notice following an intervention to improve mobility and incontinence care for nursing home residents? An analysis of open-ended comments. Gerontologist. Feb. 2007;47(1):14-20. Not eligible population. [pmid: 17327536].
2031 Lewey J, Billington A, O’Hara L. Conservative treatment of urinary incontinence. Nurs Stand. Nov 12–18. 1997;12(8):45-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9418469].
2032 Lewinshtein DJ, Perrotte P, Lebeau T, et al. Normal urinary and sexual function in men without evidence of prostate cancer from Montreal, Canada. BJU Int. Jun. 2006;97(6):1273-7. Not eligible target population. [pmid: 16686725].
2033 Lewis L. The state of the science: focus on chronic illness. Am J Nurs. Feb. 2005;105(2):27-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15674049].
2034 Lewis SA. Everything you wanted to know about the bladder epithelium but were afraid to ask. Am J Physiol Renal Physiol. Jun. 2000;278(6):F867-74. Not eligible review. [pmid: 10836974].
2035 Lewis-Abney K, Rosenkranz CF. Content validation of impaired skin integrity and urinary incontinence in the home health setting. Nurs Diagn. Jan–Mar. 1994;5(1):36-42. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8192950].
2036 Lewis-Byers K, Thayer D. An evaluation of two incontinence skin care protocols in a long-term care setting. Ostomy Wound Manage. Dec. 2002;48(12):44-51. Not eligible target population. [pmid: 12490752].
2037 Li FL, Low LP, Lee DT. Chinese women’s experiences in coping with urinary incontinence. J Clin Nurs. Mar. 2007;16(3):610-2. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17335537].
2038 Li Y, Cai X, Glance LG, et al. Gender differences in healthcare-seeking behavior for urinary incontinence and the impact of socioeconomic status: a study of the Medicare managed care population. Med Care. Nov. 2007;45(11):1116-22. Not eligible outcomes. [pmid: 18049354].
2039 Liao YM, Dougherty MC, Boyington AR, et al. Developing and validating a Chinese instrument to measure lower urinary tract symptoms among employed women in Taiwan. Nurs Outlook. Nov–Dec. 2006;54(6):353-61. no primary result. [pmid: 17142154].
2040 Liao YM, Dougherty MC, Liou YS, et al. Pelvic floor muscle training effect on urinary incontinence knowledge, attitudes, and severity: an experimental study. Int J Nurs Stud. Jan. 2006;43(1):29-37. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16326162].
2041 Liapis A, Bakas P, Christopoulos P, et al. Tension-free vaginal tape for elderly women with stress urinary incontinence. Int J Gynaecol Obstet. Jan. 2006;92(1):48-51. Not eligible exposure. [pmid: 16253254].
2042 Liapis A, Bakas P, Creatsas G. Burch colposuspension and tension-free vaginal tape in the management of stress urinary incontinence in women. Eur Urol. Apr. 2002;41(4):469-73. Not eligible exposure. [pmid: 12074820].
2043 Liapis A, Bakas P, Creatsas G. Assessment of TVT efficacy in the management of patients with genuine stress incontinence with the use of epidural vs intravenous anesthesia. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2007;18(10):1197-200. Not eligible exposure. [pmid: 17268766].
2044 Liapis A, Bakas P, Creatsas G. Monarc vs TVT-O for the treatment of primary stress incontinence: a randomized study. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2008;19(2):185-90. Not eligible exposure. [pmid: 17668144].
2045 Liapis A, Bakas P, Georgantopoulou C, et al. The use of oestradiol therapy in postmenopausal women after TVT-O anti-incontinence surgery. Maturitas. May. 2010;66(1):101-6. Not eligible target population. [pmid: 20236776].
2046 Liapis A, Bakas P, Giner M, et al. Tension-free vaginal tape versus tension-free vaginal tape obturator in women with stress urinary incontinence. Gynecol Obstet Invest. 2006;62(3):160-4. Not eligible exposure. [pmid: 16707901].
2047 Liapis A, Pyrgiotis E, Kontoravdis A, et al. Genuine stress incontinence: prospective randomized comparison of two operative methods. Eur J Obstet Gynecol Reprod Biol. Jan. 1996;64(1):69-72. Not eligible exposure. [pmid: 8801153].
2048 Liberman JN, Hunt TL, Stewart WF, et al. Health-related quality of life among adults with symptoms of overactive bladder: results from a U.S. community-based survey. Urology. Jun. 2001;57(6):1044-50. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11377301].
2049 Lieu PK, Chia HH, Heng LC, et al. Carer-assisted intermittent urethral catheterisation in the management of persistent retention of urine in elderly women. Ann Acad Med Singapore. Jul. 1996;25(4):562-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8893931].
2050 Lightner DJ. Menopause hormonal therapy from the urologist’s perspective. Curr Urol Rep. Jan. 2006;7(1):1-3. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16480661].
2051 Lilleby W, Fossa SD, Waehre HR, et al. Long-term morbidity and quality of life in patients with localized prostate cancer undergoing definitive radiotherapy or radical prostatectomy. Int J Radiat Oncol Biol Phys. Mar. 1. 1999;43(4):735-43. Not eligible target population. [pmid: 10098428].
2052 Lilly JD, Parsons CL. Bladder surface glycosaminoglycans is a human epithelial permeability barrier. Surg Gynecol Obstet. Dec. 1990;171(6):493-6. Not eligible target population. [pmid: 2244283].
2053 Lim AJ, Brandon AH, Fiedler J, et al. Quality of life: radical prostatectomy versus radiation therapy for prostate cancer. J Urol. Oct. 1995;154(4):1420-5. Not eligible target population. [pmid: 7658548].
2054 Lim HJ, Lee MS. Relation of urinary incontinence, menopausal symptoms, and life satisfaction in middle-age Korean women. Psychol Rep. Aug. 2005;97(1):203-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16279326].
2055 Lim J, Cornish A, Carey MP. Clinical and quality-of-life outcomes in women treated by the TVT-O procedure. BJOG. Nov. 2006;113(11):1315-20. Not eligible exposure. [pmid: 17059393].
2056 Lim MY, Perera M, Ramsay I, et al. Surgical management of stress urinary incontinence in Scotland and Wales: a questionnaire study. Int J Surg. Jun. 2007;5(3):162-6. Not eligible exposure. [pmid: 17509497].
2057 Lim PP, Sahadevan S, Choo GK, et al. Burden of caregiving in mild to moderate dementia: an Asian experience. Int Psychogeriatr. Dec. 1999;11(4):411-20. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10631586].
2058 Lim YM, Song J, Oh H. Translation and validation of the Korean version of MUDI and MUSIQ with urinary incontinent older men. Yonsei Med J. Feb. 28. 2009;50(1):122-31. Not eligible target population. [pmid: 19259358].
2059 Lim YN, Muller R, Corstiaans A, et al. Suburethral slingplasty evaluation study in North Queensland, Australia: the SUSPEND trial. Aust N Z J Obstet Gynaecol. Feb. 2005;45(1):52-9. Not eligible exposure. [pmid: 15730366].
2060 Lin HH, Sheu BC, Lo MC, et al. Comparison of treatment outcomes for imipramine for female genuine stress incontinence. Br J Obstet Gynaecol. Oct. 1999;106(10):1089-92. Case-series. [pmid: 10519437].
2061 Lin SY, Dougherty MC. Incontinence impact, symptom distress and treatment-seeking behavior in women with involuntary urine loss in Southern Taiwan. Int J Nurs Stud. Mar. 2003;40(3):227-34. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12605945].
2062 Lindehall B, Moller A, Hjalmas K, et al. Psychosocial factors in teenagers and young adults with myelomeningocele and clean intermittent catheterization. Scandinavian Journal of Urology & Nephrology. 2008;42(6):539-44. Not eligible target population. [pmid: 19031268].
2063 Lindgren AM, Svardsudd K, Tibblin G. Are health surveys among elderly people worthwhile? The Albertina Project. Scand J Prim Health Care. Jun. 1998;16(2):101-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9689688].
2064 Lindsay J, Sykes E, McDowell I, et al. More than the epidemiology of Alzheimer’s disease: contributions of the Canadian Study of Health and Aging. Can J Psychiatry. Feb. 2004;49(2):83-91. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15065741].
2065 Link RE, Su LM, Sullivan W, et al. Health related quality of life before and after laparoscopic radical prostatectomy. J Urol. Jan. 2005;173(1):175-9. discussion 9. Not eligible target population. [pmid: 15592069].
2066 Lionis C, Vlachonikolis L, Bathianaki M, et al. Urinary incontinence, the hidden health problem of Cretan women: report from a primary care survey in Greece. Women Health. 2000;31(4):59-66. Not eligible exposure. [pmid: 11310811].
2067 Litman HJ, Bhasin S, O’Leary MP, et al. An investigation of the relationship between sex-steroid levels and urological symptoms: results from the Boston Area Community Health survey. BJU Int. Aug. 2007;100(2):321-6. Not eligible target population. [pmid: 17506868].
2068 Little DJ, Kuban DA, Levy LB, et al. Quality-of-life questionnaire results 2 and 3 years after radiotherapy for prostate cancer in a randomized dose-escalation study. Urology. Oct. 2003;62(4):707-13. Not eligible target population. [pmid: 14550448].
2069 Litwiller SE, Frohman EM, Zimmern PE. Multiple sclerosis and the urologist. J Urol. Mar. 1999;161(3):743-57. Not eligible target population. [pmid: 10022678].
2070 Litwiller SE, Kim KB, Fone PD, et al. Post-prostatectomy incontinence and the artificial urinary sphincter: a long-term study of patient satisfaction and criteria for success. J Urol. Dec. 1996;156(6):1975-80. Not eligible target population. [pmid: 8911369].
2071 Litwiller SE, Nelson RS, Fone PD, et al. Vaginal wall sling: long-term outcome analysis of factors contributing to patients satisfaction and surgical success. J Urol. Apr. 1997;157(4):1279-82. Not eligible exposure. [pmid: 9120920].
2072 Litwin MS, Saigal CS, Yano EM, et al. Urologic diseases in America Project: analytical methods and principal findings. J Urol. Mar. 2005;173(3):933-7. Not eligible outcomes. [pmid: 15711342].
2073 Liu C, Shen W, Xie J. Nonparametric empirical Bayes method for comparison of treatment effects with application to stress urinary incontinence data. Pharm Stat. Jan–Mar. 2008;7(1):42-52. Modeling study. [pmid: 17311241].
2074 Liu HT, Chancellor MB, Kuo HC. Urinary nerve growth factor level could be a biomarker in the differential diagnosis of mixed urinary incontinence in women. BJU international. Nov. 2008;102(10):1440-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18489524].
2075 Locher JL, Burgio KL, Goode PS, et al. Effects of age and causal attribution to aging on health-related behaviors associated with urinary incontinence in older women. Gerontologist. Aug. 2002;42(4):515-21. Not eligible outcomes. [pmid: 12145379].
2076 Lockhart JL, Pow-Sang JM, Persky L, et al. Results, complications and surgical indications of the Florida pouch. Surg Gynecol Obstet. Oct. 1991;173(4):289-96. Not eligible exposure. [pmid: 1925899].
2077 Loeb S, Roehl KA, Helfand BT, et al. Complications of open radical retropubic prostatectomy in potential candidates for active monitoring. Urology. Oct. 2008;72(4):887-91. Not eligible target population. [pmid: 18329080].
2078 Loeb S, Smith ND, Roehl KA, et al. Intermediate-term potency, continence, and survival outcomes of radical prostatectomy for clinically high-risk or locally advanced prostate cancer. Urology. Jun. 2007;69(6):1170-5. Not eligible target population. [pmid: 17572209].
2079 Loening-Baucke V. Prevalence rates for constipation and faecal and urinary incontinence. Archives of Disease in Childhood. Jun. 2007;92(6):486-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16857698].
2080 Logan K, Proctor S. Developing an interdisciplinary integrated continence service. Nurs Times. May 27–Jun 2. 2003;99(21):34-7. Not eligible exposure. [pmid: 12800526].
2081 Logigian EL, Shefner JM, Goumnerova L, et al. The critical importance of stimulus intensity in intraoperative monitoring for partial dorsal rhizotomy. Muscle Nerve. Apr. 1996;19(4):415-22. Not eligible target population. [pmid: 8622718].
2082 Long CY, Hsu CS, Liu CM, et al. Clinical and ultrasonographic comparison of tension-free vaginal tape and transobturator tape procedure for the treatment of stress urinary incontinence. J Minim Invasive Gynecol. Jul–Aug. 2008;15(4):425-30. Not eligible exposure. [pmid: 18588852].
2083 Long CY, Liu CM, Wu TP, et al. A randomized comparison of vesicourethral function after laparoscopic hysterectomy with and without vaginal cuff suspension. J Minim Invasive Gynecol. Mar–Apr. 2005;12(2):137-43. Not eligible target population. [pmid: 15904617].
2084 Long R. Ingenuity encounters incontinence. Contemp Longterm Care. Jun. 2001;24(6):24-8. Not eligible target population. [pmid: 11417097].
2085 Longworth J, Davila Y, Sampselle C. La perdida de orina: Hispanic women’s experience of urinary incontinence. Hispanic Health Care International. 2003;2(1):13-21. (9). Not eligible target population.
2086 Lopez Pereira P, Miguelez C, Caffarati J, et al. Trospium chloride for the treatment of detrusor instability in children. J Urol. Nov. 2003;170(5):1978-81. Not eligible target population. [pmid: 14532838].
2087 Lord HE, Taylor JD, Finn JC, et al. A randomized controlled equivalence trial of short-term complications and efficacy of tension-free vaginal tape and suprapubic urethral support sling for treating stress incontinence. BJU Int. Aug. 2006;98(2):367-76. Not eligible exposure. [pmid: 16879679].
2088 Lorenzo AJ, Chait PG, Wallis MC, et al. Minimally invasive approach for treatment of urinary and fecal incontinence in selected patients with spina bifida. Urology. Sep. 2007;70(3):568-71. Not eligible target population. [pmid: 17905118].
2089 Lose G. Laparoscopic Burch colposuspension. Acta Obstet Gynecol Scand Suppl. 1998;168:29-33. Not eligible exposure. [pmid: 9744787].
2090 Lose G, Fantl JA, Victor A, et al. Outcome measures for research in adult women with symptoms of lower urinary tract dysfunction. Standardization Committee of the International Continence Society. Acta Obstet Gynecol Scand. Nov. 2001;80(11):981-5. guidelines. [pmid: 11703192].
2091 Lose G, Jorgensen L, Thunedborg P. Doxepin in the treatment of female detrusor overactivity: a randomized double-blind crossover study. J Urol. Oct. 1989;142(4):1024-6. Not eligible exposure. [pmid: 2795725].
2092 Lose G, Mouritsen L, Nielsen JB. A new bulking agent (polyacrylamide hydrogel) for treating stress urinary incontinence in women. BJU Int. Jul. 2006;98(1):100-4. Not eligible exposure. [pmid: 16831152].
2093 Lovatsis D, Drutz HP, Wilson D, et al. Utilization of preoperative urodynamic studies by Canadian gynaecologists. J Obstet Gynaecol Can. Apr. 2002;24(4):315-9. no associative hypothesis tested. [pmid: 12196867].
2094 Lowder JL, Weber AM. Effect of raloxifene on urinary incontinence: a randomized controlled trial. Obstet Gynecol. Jul. 2004;104(1):197-8. author reply 8. Comment. [pmid: 15229033].
2095 Lowe EM, Anand P, Terenghi G, et al. Increased nerve growth factor levels in the urinary bladder of women with idiopathic sensory urgency and interstitial cystitis. Br J Urol. Apr. 1997;79(4):572-7. Not eligible outcomes. [pmid: 9126085].
2096 Lowenstein L, Dooley Y, Kenton K, et al. The volume at which women leak first on urodynamic testing is not associated with quality of life, measures of urethral integrity or surgical failure. J Urol. Jul. 2007;178(1):193-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17499809].
2097 Lowenstein L, FitzGerald MP, Kenton K, et al. Patient-selected goals: the fourth dimension in assessment of pelvic floor disorders. Int Urogynecol J Pelvic Floor Dysfunct. Jan. 2008;19(1):81-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17497063].
2098 Lowenstein L, Kenton K, Dooley Y, et al. Women who experience detrusor overactive at lower bladder volumes report greater bother. Neurourol Urodyn. 2008;27(1):45-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17600369].
2099 Lubeck DP, Prebil LA, Peeples P, et al. A health related quality of life measure for use in patients with urge urinary incontinence: a validation study. Qual Life Res. Jun. 1999;8(4):337-44. Not eligible outcomes. [pmid: 10472166].
2100 Luber KM, Boero S, Choe JY. The demographics of pelvic floor disorders: current observations and future projections. Am J Obstet Gynecol. Jun. 2001;184(7):1496-501. discussion 501–3. Not eligible target population. [pmid: 11408873].
2101 Ludviksson K. The value of clinical examination of the female incontinent patient. Acta Obstet Gynecol Scand Suppl. 1997;166:19-23. Not eligible exposure. [pmid: 9253373].
2102 Lukacz ES, Lawrence JM, Burchette RJ, et al. The use of Visual Analog Scale in urogynecologic research: a psychometric evaluation. Am J Obstet Gynecol. Jul. 2004;191(1):165-70. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15295359].
2103 Lukacz ES, Luber KM, Nager CW. The effects of the tension-free vaginal tape on voiding function: a prospective evaluation. Int Urogynecol J Pelvic Floor Dysfunct. Jan–Feb. 2004;15(1):32-8. discussion 8. Not eligible exposure. [pmid: 14752596].
2104 Lukaz K. Urinary incontinence: suffering in isolation. Can Nurse. May. 1995;91(5):23-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7757932].
2105 Lukban JC. Suburethral sling using the transobturator approach: a quality-of-life analysis. Am J Obstet Gynecol. Dec. 2005;193(6):2138-43. Not eligible exposure. [pmid: 16325630].
2106 Luna MT, Hirakawa T, Nakano H. Urinary incontinence in women seen in the obstetrics and gynecology clinic. Int Urogynecol J Pelvic Floor Dysfunct. 2000;11(5):277-81. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11052561].
2107 Lundqvist C, Siosteen A, Blomstrand C, et al. Spinal cord injuries. Clinical, functional, and emotional status. Spine. Jan. 1991;16(1):78-83. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 2003241].
2108 MOD, Monz B, Hunskaar S. General preferences for involvement in treatment decision making among European women with urinary incontinence. Soc Sci Med. May. 2007;64(9):1914-24. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17360093].
2109 Maaita M, Bhaumik J, Davies AE. Sexual function after using tension-free vaginal tape for the surgical treatment of genuine stress incontinence. BJU Int. Oct. 2002;90(6):540-3. Not eligible exposure. [pmid: 12230613].
2110 Maake C, Landman M, Wang X, et al. Expression of smoothelin in the normal and the overactive human bladder. J Urol. Mar. 2006;175(3 Pt 1):1152-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16469643].
2111 Maas CP, ter Kuile MM, Laan E, et al. Objective assessment of sexual arousal in women with a history of hysterectomy. BJOG : an international journal of obstetrics and gynaecology. 2004:456-62. Not eligible target population. [pmid: 15104610].
2112 Macaulay M, Clarke OS, Fader M, et al. Are washable absorbents effective at containing urinary incontinence?. Nurs Times. Mar. 23–29. 2004;100(12):58-62. No associative hypothesis tested. [pmid: 15067915].
2113 Macaulay M, Clarke-O’Neill S, Fader M, et al. A pilot study to evaluate reusable absorbent body-worn products for adults with moderate/heavy urinary incontinence. J Wound Ostomy Continence Nurs. Nov–Dec. 2004;31(6):357-66. Not eligible target population. [pmid: 15867711].
2114 Macaulay M, Henry G. Continence. Drop in and do well. Nurs Times. Nov. 14–20. 1990;86(46):65-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 2082302].
2115 Macaulay M, Pettersson L, Fader M, et al. A multicenter evaluation of absorbent products for children with incontinence and disabilities. J Wound Ostomy Continence Nurs. Jul–Aug. 2004;31(4):235-44. Not eligible target population. [pmid: 15851868].
2116 MacDiarmid S, Rosenberg M. Overactive bladder in women: symptom impact and treatment expectations. Curr Med Res Opin. Sep. 2005;21(9):1413-21. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16197660].
2117 MacDiarmid SA, Peters KM, Chen A, et al. Efficacy and safety of extended-release oxybutynin in combination with tamsulosin for treatment of lower urinary tract symptoms in men: randomized, double-blind, placebo-controlled study. Mayo Clin Proc. Sep. 2008;83(9):1002-10. Not eligible target population. [pmid: 18775200].
2118 MacDonagh RP, Forster DM, Thomas DG. Urinary continence in spinal injury patients following complete sacral posterior rhizotomy. Br J Urol. Dec. 1990;66(6):618-22. Not eligible target population. [pmid: 2265335].
2119 MacDonald CD, Butler L. Silent no more: elderly women’s stories of living with urinary incontinence in long-term care. J Gerontol Nurs. Jan. 2007;33(1):14-20. Not eligible target population. [pmid: 17305265].
2120 MacInnes CL. Why women leave therapy for stress incontinence. Nurs Times. Oct. 14–20. 2008;104(41):50-3. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18979961].
2121 MacKay K, Hemmett L. Needs assessment of women with urinary incontinence in a district health authority. Br J Gen Pract. Oct. 2001;51(471):801-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11677702].
2122 MacLennan AH, Taylor AW, Wilson DH, et al. The prevalence of pelvic floor disorders and their relationship to gender, age, parity and mode of delivery. BJOG. Dec. 2000;107(12):1460-70. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11192101].
2123 Macura KJ, Genadry RR, Bluemke DA. Role of MR Imaging in Diagnosis of Urethra Hypermobility and Intrinsic Sphincter Deficiency in Women with Stress Urinary Incontinence. Paper presented at: 14th Scientific Meeting and Exhibition of the International Society for Magnetic Resonance in Medicine (ISMRM 2006), Washington State Convention & Trade Center. Seattle, Washington (USA). 6–12 May 2006. Not eligible exposure.
2124 Madalinska JB, Essink-Bot ML, de Koning HJ, et al. Health-related quality-of-life effects of radical prostatectomy and primary radiotherapy for screen-detected or clinically diagnosed localized prostate cancer. J Clin Oncol. Mar. 15. 2001;19(6):1619-28. Not eligible target population. [pmid: 11250990].
2125 Madersbacher H, Jilg G. Control of detrusor hyperreflexia by the intravesical instillation of oxybutynine hydrochloride. Paraplegia. Feb. 1991;29(2):84-90. Not eligible exposure. [pmid: 2023781].
2126 Madersbacher S, Pycha A, Klingler CH, et al. The International Prostate Symptom score in both sexes: a urodynamics-based comparison. Neurourol Urodyn. 1999;18(3):173-82. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10338437].
2127 Madersbacher S, Pycha A, Schatzl G, et al. The aging lower urinary tract: a comparative urodynamic study of men and women. Urology. Feb. 1998;51(2):206-12. Not eligible exposure. [pmid: 9495699].
2128 Madjar S, Covington-Nichols C, Secrest CL. New periurethral bulking agent for stress urinary incontinence: modified technique and early results. J Urol. Dec. 2003;170(6 Pt 1):2327-9. Not eligible exposure. [pmid: 14634407].
2129 Madjar S, Evans D, Duncan RC, et al. Collaboration and practice patterns among urologists and gynecologists in the treatment of urinary incontinence and pelvic floor prolapse: a survey of the International Continence Society members. Neurourol Urodyn. 2001;20(1):3-11. Not eligible target population. [pmid: 11135377].
2130 Madjar S, Wald M, Halachmi S, et al. Minimally invasive pervaginam procedures for the treatment of female stress incontinence using a new pubic bone anchoring system. Artif Organs. Oct. 1998;22(10):879-85. Not eligible exposure. [pmid: 9790087].
2131 Magera JS Jr, Elliott DS. Tandem transcorporal artificial urinary sphincter cuff salvage technique: surgical description and results. J Urol. Mar. 2007;177(3):1015-9. discussion 9–20. Not eligible exposure. [pmid: 17296400].
2132 Magera JS Jr, Inman BA, Elliott DS. Outcome analysis of urethral wall stent insertion with artificial urinary sphincter placement for severe recurrent bladder neck contracture following radical prostatectomy. J Urol. Mar. 2009;181(3):1236-41. Not eligible target population. [pmid: 19152938].
2133 Maggi S, Minicuci N, Langlois J, et al. Prevalence rate of urinary incontinence in community-dwelling elderly individuals: the Veneto study. J Gerontol A Biol Sci Med Sci. Jan. 2001;56(1):M14-8. no associative hypothesis tested. [pmid: 11193226].
2134 Mahajan ST, Elkadry EA, Kenton KS, et al. Patient-centered surgical outcomes: the impact of goal achievement and urge incontinence on patient satisfaction one year after surgery. American Journal of Obstetrics & Gynecology. Mar. 2006;194(3):722-8. Not eligible exposure. [pmid: 16522404].
2135 Mahawong P, Chaiyaprasithi B, Soontrapa S, et al. A role of intravesical capsaicin instillation in benign prostatic hyperplasia with overactive bladder symptoms: the first reported study in the literature. J Med Assoc Thai. Nov. 2007;90(11):2301-9. Not eligible target population. [pmid: 18181311].
2136 Maher C, Baessler K, Glazener CM, et al. Surgical management of pelvic organ prolapse in women. Cochrane Database Syst Rev. 2004;(4):CD004014. Not eligible exposure. [pmid: 15495076].
2137 Maher C, Dwyer P, Carey M, et al. The Burch colposuspension for recurrent urinary stress incontinence following retropubic continence surgery. Br J Obstet Gynaecol. Jul. 1999;106(7):719-24. Not eligible exposure. [pmid: 10428530].
2138 Maher CF, O’Reilly BA, Dwyer PL, et al. Pubovaginal sling versus transurethral Macroplastique for stress urinary incontinence and intrinsic sphincter deficiency: a prospective randomised controlled trial. BJOG. Jun. 2005;112(6):797-801. Not eligible exposure. [pmid: 15924540].
2139 Major H, Culligan P, Heit M. Urethral sphincter morphology in women with detrusor instability. Obstetrics and gynecology. 2002:63-8. Not eligible exposure. [pmid: 11777512].
2140 Makinen JI, Pitkanen YA, Salmi TA, et al. Transdermal estrogen for female stress urinary incontinence in postmenopause. Maturitas. Nov. 1995;22(3):233-8. Case-series. [pmid: 8746881].
2141 Malhotra B, Gandelman K, Sachse R, et al. Assessment of the effects of renal impairment on the pharmacokinetic profile of fesoterodine. J Clin Pharmacol. Apr. 2009;49(4):477-82. Not eligible outcomes. [pmid: 19246724].
2142 Malhotra B, Guan Z, Wood N, et al. Pharmacokinetic profile of fesoterodine. Int J Clin Pharmacol Ther. Nov. 2008;46(11):556-63. Not eligible outcomes. [pmid: 19000553].
2143 Malhotra B, Sachse R, Wood N. Evaluation of drug-drug interactions with fesoterodine. Eur J Clin Pharmacol. Jun. 2009;65(6):551-60. Not eligible outcomes. [pmid: 19347334].
2144 Malhotra BK, Crownover PH, LaBadie R, et al. The pharmacokinetic profile of fesoterodine 8 mg with daytime or nighttime dosing. Eur J Clin Pharmacol. Feb. 2010;66(2):171-6. Not eligible outcomes. [pmid: 19915829].
2145 Maliski SL, Litwin MS. Unsolicited written comments: an untapped data source. Oncol Nurs Forum. Jan. 2007;34(1):142-7. Not eligible target population. [pmid: 17562641].
2146 Mallett VT, Brubaker L, Stoddard AM, et al. The expectations of patients who undergo surgery for stress incontinence. Am J Obstet Gynecol. Mar. 2008;198(3):308 e1-6. Not eligible exposure. [pmid: 18313452].
2147 Mallipeddi PK, Steele AC, Kohli N, et al. Anatomic and functional outcome of vaginal paravaginal repair in the correction of anterior vaginal wall prolapse. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(2):83-8. Not eligible exposure. [pmid: 11374518].
2148 Malone DC, Okano GJ. Treatment of urge incontinence in Veterans Affairs medical centers. Clin Ther. May. 1999;21(5):867-77. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10397381].
2149 Malone PS, Wheeler RA, Williams JE. Continence in patients with spina bifida: long term results. Arch Dis Child. Feb. 1994;70(2):107-10. Not eligible target population. [pmid: 8129429].
2150 Malone-Lee J. Know how. Managing incontinence. Nurs Times. May. 5–11. 1999;95(18):74-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10373917].
2151 Malone-Lee J, Shaffu B, Anand C, et al. Tolterodine: superior tolerability than and comparable efficacy to oxybutynin in individuals 50 years old or older with overactive bladder: a randomized controlled trial. The Journal of urology. 2001:1452-6. Not eligible target population. [pmid: 11342895].
2152 Manassero F, Traversi C, Ales V, et al. Contribution of early intensive prolonged pelvic floor exercises on urinary continence recovery after bladder neck-sparing radical prostatectomy: results of a prospective controlled randomized trial. Neurourol Urodyn. 2007;26(7):985-9. Not eligible target population. [pmid: 17487874].
2153 Manca A, Sculpher MJ, Ward K, et al. A cost-utility analysis of tension-free vaginal tape versus colposuspension for primary urodynamic stress incontinence. BJOG. Mar. 2003;110(3):255-62. Not eligible exposure. [pmid: 12628263].
2154 Mancini JG, Kizer WS, Jones LA, et al. Patient satisfaction after dual implantation of inflatable penile and artificial urinary sphincter prostheses. Urology. May. 2008;71(5):893-6. Not eligible target population. [pmid: 18374398].
2155 Mangnall J, Taylor P, Thomas S, et al. Continence problems in care homes: auditing assessment and treatment. Nurs Older People. Mar. 2006;18(2):20-2. Not eligible target population. [pmid: 16538991].
2156 Manhes H. Laparoscopic Retzio-plasty. A new surgical approach to stress incontinence. Int Surg. Oct–Dec. 1996;81(4):371-3. Not eligible exposure. [pmid: 9127797].
2157 Manikandan R, Kujawa M, Pearson E, et al. Results of the tension-free vaginal tape procedure for stress incontinence: patient’s perspective. Int J Urol. Apr. 2004;11(4):206-12. Not eligible exposure. [pmid: 15028098].
2158 Manonai J, Poowapirom A, Kittipiboon S, et al. Female urinary incontinence: a cross-sectional study from a Thai rural area. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2006;17(4):321-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16184317].
2159 Mansi MK. Continent urinary undiversion to modified ureterosigmoidostomy in bladder extrophy patients. World J Surg. Feb. 1999;23(2):207-13. Not eligible exposure. [pmid: 9880434].
2160 Mansson A, Anderson H, Colleen S. Time lag to diagnosis of bladder cancer--influence of psychosocial parameters and level of health-care provision. Scand J Urol Nephrol. 1993;27(3):363-9. Not eligible target population. [pmid: 8290917].
2161 Mansson-Lindstrom A, Dehlin O, Isacsson A. Quality by selection and purchasing of urinary incontinence aids-- perceptions of nurses and administrators. Scand J Caring Sci. 1994;8(2):87-94. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7886331].
2162 Mansson-Lindstrom A, Dehlin O, Isacsson A. Urinary incontinence in primary health care. 2. Care routines and consequences--perception of various categories of nursing personnel and care units. Scand J Prim Health Care. Sep. 1994;12(3):175-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7997695].
2163 Marchand JE, Sant GR, Kream RM. Increased expression of substance P receptor-encoding mRNA in bladder biopsies from patients with interstitial cystitis. Br J Urol. Feb. 1998;81(2):224-8. Not eligible outcomes. [pmid: 9488063].
2164 Mardon RE, Halim S, Pawlson LG, et al. Management of urinary incontinence in Medicare managed care beneficiaries: results from the 2004 Medicare Health Outcomes Survey. Arch Intern Med. May. 22. 2006;166(10):1128-33. Not eligible outcomes. [pmid: 16717176].
2165 Margalith I, Gillon G, Gordon D. Urinary incontinence in women under 65: quality of life, stress related to incontinence and patterns of seeking health care. Qual Life Res. Oct. 2004;13(8):1381-90. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15503833].
2166 Mariappan P, Chong WL. Prevalence and correlations of lower urinary tract symptoms, erectile dysfunction and incontinence in men from a multiethnic Asian population: Results of a regional population-based survey and comparison with industrialized nations. BJU Int. Dec. 2006;98(6):1264-8. Not eligible target population. [pmid: 17034498].
2167 Marinkovic SP, Stanton SL. Triple compartment prolapse: sacrocolpopexy with anterior and posterior mesh extensions. BJOG. Mar. 2003;110(3):323-6. Not eligible exposure. [pmid: 12628277].
2168 Mariotti G, Sciarra A, Gentilucci A, et al. Early recovery of urinary continence after radical prostatectomy using early pelvic floor electrical stimulation and biofeedback associated treatment. J Urol. Apr. 2009;181(4):1788-93. Not eligible target population. [pmid: 19233390].
2169 Markland AD, Kraus SR, Richter HE, et al. Prevalence and risk factors of fecal incontinence in women undergoing stress incontinence surgery. Am J Obstet Gynecol. Dec. 2007;197(6):662 e1-7. Not eligible exposure. [pmid: 18060972].
2170 Markland AD, Richter HE, Burgio KL, et al. Fecal incontinence in obese women with urinary incontinence: prevalence and role of dietary fiber intake. Am J Obstet Gynecol. May. 2009;200(5):566 e1-6. Not eligible target population. [pmid: 19136088].
2171 Markland AD, Richter HE, Kenton KS, et al. Associated factors and the impact of fecal incontinence in women with urge urinary incontinence: from the Urinary Incontinence Treatment Network’s Behavior Enhances Drug Reduction of Incontinence study. Am J Obstet Gynecol. Apr. 2009;200(4):424 e1-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 19200939].
2172 Marklund-Bau H, Edell-Gustafsson U, Spangberg A. Bothersome urinary symptoms and disease-specific quality of life in patients with benign prostatic obstruction. Scand J Urol Nephrol. 2007;41(1):32-41. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17366100].
2173 Marschall-Kehrel D, Feustel C, Persson de Geeter C, et al. Treatment with propiverine in children suffering from nonneurogenic overactive bladder and urinary incontinence: results of a randomized placebo-controlled phase 3 clinical trial. Eur Urol. Mar. 2009;55(3):729-36. Not eligible target population. [pmid: 18502028].
2174 Marshall DF, Boston VE. Altered bladder and bowel function following cutaneous electrical field stimulation in children with spina bifida--interim results of a randomized double-blind placebo-controlled trial. Eur J Pediatr Surg. Dec. 1997;7(Suppl 1):41-3. Not eligible target population. [pmid: 9497117].
2175 Marshall HJ, Beevers DG. Alpha-adrenoceptor blocking drugs and female urinary incontinence: prevalence and reversibility. Br J Clin Pharmacol. Oct. 1996;42(4):507-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8904625].
2176 Martignoni E, Nappi RE, Citterio A, et al. Reproductive life milestones in women with Parkinson’s disease. Funct Neurol. Oct–Dec. 2003;18(4):211-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15055746].
2177 Martinez AM, Ramos NM, Requena JF, et al. Analysis of retropubic colpourethrosuspension results by suburethral sling with REMEEX prosthesis. Eur J Obstet Gynecol Reprod Biol. Feb. 10. 2003;106(2):179-83. Not eligible exposure. [pmid: 12551789].
2178 Martis G, Diana M, Ombres M, et al. Retropubic versus perineal radical prostatectomy in early prostate cancer: eight-year experience. J Surg Oncol. May. 1. 2007;95(6):513-8. Not eligible target population. [pmid: 17226809].
2179 Maruyama S, Oki T, Otsuka A, et al. Human muscarinic receptor binding characteristics of antimuscarinic agents to treat overactive bladder. J Urol. Jan. 2006;175(1):365-9. Not eligible target population. [pmid: 16406943].
2180 Mascarenhas F, Cocuzza M, Gomes CM, et al. Trigonal injection of botulinum toxin-A does not cause vesicoureteral reflux in neurogenic patients. Neurourology & Urodynamics. 2008;27(4):311-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17914742].
2181 Mashidori T, Yamanishi T, Yoshida K, et al. Continuous urinary incontinence presenting as the initial symptoms demonstrating acontractile detrusor and intrinsic sphincter deficiency in multiple system atrophy. International Journal of Urology. Oct. 2007;14(10):972-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17880306].
2182 Mason L, Glenn S, Walton I, et al. The experience of stress incontinence after childbirth. Birth. Sep. 1999;26(3):164-71. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10655816].
2183 Mason L, Glenn S, Walton I, et al. The instruction in pelvic floor exercises provided to women during pregnancy or following delivery. Midwifery. Mar. 2001;17(1):55-64. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11207105].
2184 Mason L, Glenn S, Walton I, et al. Women’s reluctance to seek help for stress incontinence during pregnancy and following childbirth. Midwifery. Sep. 2001;17(3):212-21. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11502141].
2185 Mason M, Tully S. Urinary incontinence in the older acute care population: effects of knowledge, attitudes and beliefs of nurses on continence management. Perspectives. Fall. 2002;26(3):4-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12476599].
2186 Mason RC, Roach M. Modified pubovaginal sling for treatment of intrinsic sphincteric deficiency. J Urol. Dec. 1996;156(6):1991-4. Not eligible exposure. [pmid: 8965334].
2187 Masood S, Djaladat H, Kouriefs C, et al. The 12-year outcome analysis of an endourethral wallstent for treating benign prostatic hyperplasia. BJU Int. Dec. 2004;94(9):1271-4. Not eligible target population. [pmid: 15610103].
2188 Massolt ET, Wooning MM, Stijnen T, et al. Prevalence, impact on the quality of life and pathophysiological determinants of nocturia in urinary incontinent women. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2005;16(2):132-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15789146].
2189 Masson DB, Govier FE. Modified Pereyra bladder neck suspension in patients with intrinsic sphincter deficiency and bladder neck hypermobility: patient satisfaction with a mean follow-up of 4 years. Urology. Feb. 2000;55(2):217-21. discussion 21–2. Not eligible exposure. [pmid: 10688082].
2190 Massoud R, Federici G, Casciani S, et al. Extraction and determination of oxybutynin in human bladder samples by reversed-phase high-performance liquid chromatography. J Chromatogr B Biomed Sci Appl. Oct. 29. 1999;734(1):163-7. Not eligible target population. [pmid: 10574202].
2191 Matharu GS, Assassa RP, Williams KS, et al. Continence nurse treatment of women’s urinary symptoms. Br J Nurs. Feb. 12–25. 2004;13(3):140-3. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14997075].
2192 Mather KF, Bakas T. Nursing assistants’ perceptions of their ability to provide continence care. Geriatr Nurs. Mar–Apr. 2002;23(2):76-81. Not eligible target population. [pmid: 11956519].
2193 Mathews RI, Gan M, Gearhart JP. Urogynaecological and obstetric issues in women with the exstrophy-epispadias complex. BJU Int. Jun. 2003;91(9):845-9. Not eligible exposure. [pmid: 12780845].
2194 Mathewson-Chapman M. Pelvic muscle exercise/biofeedback for urinary incontinence after prostatectomy: an education program. J Cancer Educ. Winter. 1997;12(4):218-23. Not eligible target population. [pmid: 9440013].
2195 Matoka DJ, Averch TD. Predictability of irritative voiding symptoms following photoselective laser vaporization of the prostate. Can J Urol. Oct. 2007;14(5):3710-4. Not eligible target population. [pmid: 17949529].
2196 Matsubara A, Yasumoto H, Mutaguchi K, et al. Impact of radical perineal prostatectomy on urinary continence and quality of life: a longitudinal study of Japanese patients. Int J Urol. Nov. 2005;12(11):953-8. Not eligible target population. [pmid: 16351650].
2197 Matsukawa Y, Hattori R, Yoshikawa Y, et al. Declined Urethral Sphincter Function Related to Aging Contributes to Urinary Incontinence after Radical Prostatectomy. Paper presented at: 2008 Annual Meeting of the American Urological Association. Orlando, Florida (USA). 17–22 May 2008. Not eligible target population.
2198 Matsuoka N, Moriya Y, Akasu T, et al. Long-term outcome of urinary function after extended lymphadenectomy in patients with distal rectal cancer. Eur J Surg Oncol. Mar. 2001;27(2):165-9. Not eligible target population. [pmid: 11289753].
2199 Matsuyama H, Hirata H, Tomimatsu T, et al. Follow up of surgical repair of female pelvic floor disorders by a mailed questionnaire. Int J Urol. Apr. 2006;13(4):389-94. Not eligible exposure. [pmid: 16734856].
2200 Mavuduru RM, Mandal AK, Singh SK, et al. Comparison of HoLEP and TURP in terms of efficacy in the early postoperative period and perioperative morbidity. Urol Int. 2009;82(2):130-5. Not eligible target population. [pmid: 19321996].
2201 Mayne CJ, Assassa RP. Epidemiology of incontinence and prolapse. BJOG. Dec. 2004;111(Suppl 1):2-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15663148].
2202 Mayo NE, Gloutney L, Levy AR. A randomized trial of identification bracelets to prevent falls among patients in a rehabilitation hospital. Arch Phys Med Rehabil. Dec. 1994;75(12):1302-8. Not eligible target population. [pmid: 7993168].
2203 Mazouni C, Bladou F, Karsenty G, et al. Minimally invasive surgery for female urinary incontinence: experience with periurethral microballoon implantation. J Endourol. Nov. 2004;18(9):901-5. discussion 5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15659930].
2204 Mazouni C, Karsenty G, Bretelle F, et al. Urinary complications and sexual function after the tension-free vaginal tape procedure. Acta Obstet Gynecol Scand. Oct. 2004;83(10):955-61. Not eligible exposure. [pmid: 15453893].
2205 Mazur DJ, Hickman DH. Patient preferences: survival vs quality-of-life considerations. J Gen Intern Med. Jul. 1993;8(7):374-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8410398].
2206 Mazur DJ, Merz JF. Older patients’ willingness to trade off urologic adverse outcomes for a better chance at five-year survival in the clinical setting of prostate cancer. J Am Geriatr Soc. Sep. 1995;43(9):979-84. Not eligible target population. [pmid: 7657938].
2207 McAndrew HF, Malone PS. Continent catheterizable conduits: which stoma, which conduit and which reservoir?. BJU Int. Jan. 2002;89(1):86-9. Not eligible target population. [pmid: 11849168].
2208 McBride AW, Ellerkmann RM, Bent AE, et al. Comparison of long-term outcomes of autologous fascia lata slings with Suspend Tutoplast fascia lata allograft slings for stress incontinence. Am J Obstet Gynecol. May. 2005;192(5):1677-81. Not eligible exposure. [pmid: 15902176].
2209 McCallum TJ, Moore KN, Griffiths D. Urinary incontinence after radical prostatectomy: implications and urodynamics. Urol Nurs. Apr. 2001;21(2):113-9. 24. Not eligible target population. [pmid: 11998279].
2210 McCammon KA, Kolm P, Main B, et al. Comparative quality-of-life analysis after radical prostatectomy or external beam radiation for localized prostate cancer. Urology. Sep. 1999;54(3):509-16. Not eligible target population. [pmid: 10475363].
2211 McCarthy M, Addington-Hall J, Altmann D. The experience of dying with dementia: a retrospective study. Int J Geriatr Psychiatry. Mar. 1997;12(3):404-9. Not eligible target population. [pmid: 9152728].
2212 McCarthy M, Lay M, Addington-Hall J. Dying from heart disease. J R Coll Physicians Lond. Jul–Aug. 1996;30(4):325-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8875378].
2213 McClish DK, Wyman JF, Sale PG, et al. Use and costs of incontinence pads in female study volunteers. Continence Program for Women Research Group. J Wound Ostomy Continence Nurs. Jul. 1999;26(4):207-8. 10. 3. Not eligible outcomes. [pmid: 10476176].
2214 McClurg D, Ashe RG, Lowe-Strong AS. Neuromuscular electrical stimulation and the treatment of lower urinary tract dysfunction in multiple sclerosis--a double blind, placebo controlled, randomised clinical trial. Neurourol Urodyn. 2008;27(3):231-7. Not eligible target population. [pmid: 17705160].
2215 McConnell ES, Lekan-Rutledge D, Nevidjon B, et al. Complexity theory: a long-term care specialty practice exemplar for the education of advanced practice nurses. J Nurs Educ. Feb. 2004;43(2):84-7. Not eligible target population. [pmid: 14974517].
2216 McConnell JD, Roehrborn CG, Bautista OM, et al. The long-term effect of doxazosin, finasteride, and combination therapy on the clinical progression of benign prostatic hyperplasia. N Engl J Med. Dec. 18. 2003;349(25):2387-98. Not eligible target population. [pmid: 14681504].
2217 McCormick KA. From clinical trial to health policy--research on urinary incontinence in the adult, Part II. J Prof Nurs. Jul–Aug. 1991;7(4):202. Not eligible target population. [pmid: 1894834].
2218 McDowell BJ, Burgio KL, Dombrowski M, et al. An interdisciplinary approach to the assessment and behavioral treatment of urinary incontinence in geriatric outpatients. J Am Geriatr Soc. Apr. 1992;40(4):370-4. Not eligible case series. [pmid: 1556364].
2219 McDowell BJ, Silverman M, Martin D, et al. Identification and intervention for urinary incontinence by community physicians and geriatric assessment teams. J Am Geriatr Soc. May. 1994;42(5):501-5. Not eligible exposure. [pmid: 8176144].
2220 McDowell D, Ashe RG, Marshall K, et al. Comparison of pelvic floor muscle training, electromyography biofeedback, and neuromuscular electrical stimulation for bladder dysfunction in people with multiple sclerosis: a randomized pilot study. Neurourol Urodyn. 2006;25(4):337-48. Not eligible target population. [pmid: 16637070].
2221 McElveen TL, Waterman FM, Kim H, et al. Factors predicting for urinary incontinence after prostate brachytherapy. Int J Radiat Oncol Biol Phys. Aug. 1. 2004;59(5):1395-404. Not eligible target population. [pmid: 15275725].
2222 McGhee M, O’Neill K, Major K, et al. Evaluation of a nurse-led continence service in the south-west of Glasgow, Scotland. J Adv Nurs. Oct. 1997;26(4):723-8. Not eligible target population. [pmid: 9354984].
2223 McGlynn B, Al-Saffar N, Begg H, et al. Management of urinary incontinence following radical prostatectomy. Urol Nurs. Dec. 2004;24(6):475-82. 515. Not eligible target population. [pmid: 15658733].
2224 McGrother CW, Donaldson MM, Shaw C, et al. Storage symptoms of the bladder: prevalence, incidence and need for services in the UK. BJU Int. Apr. 2004;93(6):763-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15049987].
2225 McKinlay JB, Link CL. Measuring the urologic iceberg: design and implementation of the Boston Area Community Health (BACH) Survey. Eur Urol. Aug. 2007;52(2):389-96. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17383808].
2226 McLennan MT, Alten B, Melick C, et al. Patients’ satisfaction with and attitudes toward vaginal delivery. J Reprod Med. Oct. 2005;50(10):740-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16320554].
2227 McLennan MT, Melick CF, Alten B, et al. Patients’ knowledge of potential pelvic floor changes associated with pregnancy and delivery. Int Urogynecol J Pelvic Floor Dysfunct. Jan. 2006;17(1):22-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16003482].
2228 McLennan MT, Theofrastous JP, Melick CF. Randomized trial of cefazolin prophylaxis for open burch retropubic urethropexy. Journal of Pelvic Medicine & Surgery. 2004:239-44. Not eligible exposure.
2229 McMurdo ME, Davey PG, Elder MA, et al. A cost-effectiveness study of the management of intractable urinary incontinence by urinary catheterisation or incontinence pads. J Epidemiol Community Health. Jun. 1992;46(3):222-6. Not eligible exposure. [pmid: 1645076].
2230 McPherson CP, Swenson KK, Kjellberg J. Quality of life in patients with prostate cancer. Semin Oncol Nurs. May. 2001;17(2):138-46. Not eligible target population. [pmid: 11383245].
2231 McVeigh C. Perimenopause: more than hot flushes and night sweats for some Australian women. J Obstet Gynecol Neonatal Nurs. Jan–Feb. 2005;34(1):21-7. not eligible outcomes. [pmid: 15673642].
2232 Meade-D’Alisera P, Merriweather T, Wentland M. Impact of commercial marketing on patient demand. Urol Nurs. Dec. 2001;21(6):406-7. 10. not eligible outcomes. [pmid: 11998507].
2233 Medina CA, Takacs P. Shortening the process of determining postvoid residual. Int J Gynaecol Obstet. Dec. 2005;91(3):266-7. Not eligible outcomes. [pmid: 16226756].
2234 Mehnert U, Reitz A, Youssef SA, et al. Proof of principle: The effect of antimuscarinics on bladder filling sensations in healthy subjects--a placebo controlled double blind investigation using 4 and 8 mg tolterodine extended release. Neurourol Urodyn. Mar. 2010;29(3):464-9. Not eligible outcomes. [pmid: 19637377].
2235 Meier U, Kiefer M, Sprung C. Evaluation of the Miethke dual- switch valve in patients with normal pressure hydrocephalus. Surg Neurol. Feb. 2004;61(2):119-27. discussion 27–8. Not eligible exposure. [pmid: 14751612].
2236 Melin I, Falconer C, Rossner S, et al. Sexual function in obese women: impact of lower urinary tract dysfunction. Int J Obes (Lond). Aug. 2008;32(8):1312-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18475273].
2237 Mellier G, Benayed B, Bretones S, et al. Suburethral tape via the obturator route: is the TOT a simplification of the TVT?. Int Urogynecol J Pelvic Floor Dysfunct. Jul–Aug. 2004;15(4):227-32. Not eligible exposure. [pmid: 15517665].
2238 Mellier G, Mistrangelo E, Gery L, et al. Tension-free obturator tape (Monarc Subfascial Hammock) in patients with or without associated procedures. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2007;18(2):165-72. Not eligible exposure. [pmid: 16773232].
2239 Meltomaa SS, Haarala MA, Taalikka MO, et al. Outcome of Burch retropubic urethropexy and the effect of concomitant abdominal hysterectomy: a prospective long-term follow-up study. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(1):3-8. Not eligible exposure. [pmid: 11294528].
2240 Melville JL, Delaney K, Newton K, et al. Incontinence severity and major depression in incontinent women. Obstet Gynecol. Sep. 2005;106(3):585-92. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16135592].
2241 Melville JL, Fan MY, Newton K, et al. Fecal incontinence in US women: a population-based study. Am J Obstet Gynecol. Dec. 2005;193(6):2071-6. Not eligible target population. [pmid: 16325618].
2242 Melville JL, Katon W, Delaney K, et al. Urinary incontinence in US women: a population-based study. Arch Intern Med. Mar. 14. 2005;165(5):537-42. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15767530].
2243 Melville JL, Miller EA, Fialkow MF, et al. Relationship between patient report and physician assessment of urinary incontinence severity. Am J Obstet Gynecol. Jul. 2003;189(1):76-80. no associative hypothesis tested. [pmid: 12861142].
2244 Melville JL, Newton K, Fan MY, et al. Health care discussions and treatment for urinary incontinence in U.S. women. Am J Obstet Gynecol. Mar. 2006;194(3):729-37. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16522405].
2245 Melville JL, Wagner LE, Fan MY, et al. Women’s perceptions about the etiology of urinary incontinence. J Womens Health (Larchmt). Sep. 2008;17(7):1093-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18774894].
2246 Melville JL, Walker E, Katon W, et al. Prevalence of comorbid psychiatric illness and its impact on symptom perception, quality of life, and functional status in women with urinary incontinence. Am J Obstet Gynecol. Jul. 2002;187(1):80-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12114892].
2247 Menarini M, Del Popolo G, Di Benedetto P, et al. Trospium chloride in patients with neurogenic detrusor overactivity: is dose titration of benefit to the patients?. Int J Clin Pharmacol Ther. Dec. 2006;44(12):623-32. Not eligible target population. [pmid: 17190372].
2248 Menon M, Muhletaler F, Campos M, et al. Assessment of early continence after reconstruction of the periprostatic tissues in patients undergoing computer assisted (robotic) prostatectomy: results of a 2 group parallel randomized controlled trial. J Urol. Sep. 2008;180(3):1018-23. Not eligible target population. [pmid: 18639300].
2249 Merrick GS, Butler WM, Lief JH, et al. Temporal resolution of urinary morbidity following prostate brachytherapy. Int J Radiat Oncol Biol Phys. Apr. 1. 2000;47(1):121-8. Not eligible target population. [pmid: 10758313].
2250 Merrick GS, Butler WM, Wallner K, et al. Permanent prostate brachytherapy-induced morbidity in patients with grade II and III obesity. Urology. Jul. 2002;60(1):104-8. Not eligible target population. [pmid: 12100933].
2251 Merrick GS, Butler WM, Wallner KE, et al. Long-term urinary quality of life after permanent prostate brachytherapy. Int J Radiat Oncol Biol Phys. Jun. 1. 2003;56(2):454-61. Not eligible target population. [pmid: 12738320].
2252 Meschia M, Bertozzi R, Pifarotti P, et al. Peri-operative morbidity and early results of a randomised trial comparing TVT and TVT-O. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2007;18(11):1257-61. Not eligible exposure. [pmid: 17345002].
2253 Meschia M, Bruschi F, Amicarelli F, et al. The sacrospinous vaginal vault suspension: Critical analysis of outcomes. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(3):155-9. Not eligible exposure. [pmid: 10430007].
2254 Meschia M, Pifarotti P, Bernasconi F, et al. Tension-free vaginal tape (TVT) and intravaginal slingplasty (IVS) for stress urinary incontinence: a multicenter randomized trial. Am J Obstet Gynecol. Nov. 2006;195(5):1338-42. Not eligible exposure. [pmid: 16769016].
2255 Meschia M, Pifarotti P, Spennacchio M, et al. A randomized comparison of tension-free vaginal tape and endopelvic fascia plication in women with genital prolapse and occult stress urinary incontinence. Am J Obstet Gynecol. Mar. 2004;190(3):609-13. Not eligible exposure. [pmid: 15041988].
2256 Messer KL, Herzog AR, Seng JS, et al. Evaluation of a mass mailing recruitment strategy to obtain a community sample of women for a clinical trial of an incontinence prevention intervention. Int Urol Nephrol. 2006;38(2):255-61. Not eligible target population. [pmid: 16868693].
2257 Metello J, Nogueira B, Torgal M, et al. Comparison of the efficacy and tolerability of solifenacin succinate with or without previous use of trospium chloride. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2007;18(9):1021-5. Level of evidence. [pmid: 17211528].
2258 Meyer S, Hohlfeld P, Achtari C, et al. Pelvic floor education after vaginal delivery. Obstetrics and gynecology. 2001:673-7. Not eligible target population. [pmid: 11339914].
2259 Meyer S, Kuntzer T, Newsom N, et al. Stress urinary incontinence due to a low-pressure urethra: a socially invalidizing disease. Neurourol Urodyn. 1996;15(3):177-86. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8732984].
2260 Mezey M, Lavizzo-Mourey RJ, Brunswick J, et al. Consensus among geriatric experts on the components of a complete nursing-home admission assessment. Nurse Pract. Jun. 3. 1992;17(6):50-6. 61. Not eligible target population. [pmid: 1608570].
2261 Michel MC, de la Rosette JJ, Piro M, et al. Comparison of symptom severity and treatment response in patients with incontinent and continent overactive bladder. Eur Urol. Jul. 2005;48(1):110-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15967259].
2262 Midthun S, Paur R, Bruce AW, et al. A survey regarding the use of the dipstick/pad method with elderly, incontinent patients. J Wound Ostomy Continence Nurs. Jul–Aug. 2006;33(4):402-7. no associated hypothesis tested. [pmid: 16932123].
2263 Migliari R, Pistolesi D, Leone P, et al. Male bulbourethral sling after radical prostatectomy: intermediate outcomes at 2 to 4-year followup. J Urol. Nov. 2006;176(5):2114-8. discussion 8. Not eligible target population. [pmid: 17070273].
2264 Mikkelsen AL, Felding C, Clausen HV. Clinical effects of preoperative oestradiol treatment before vaginal repair operation. A double-blind, randomized trial. Gynecol Obstet Invest. 1995;40(2):125-8. Not eligible exposure. [pmid: 8575690].
2265 Miles BJ, Khera M. Can preoperative behavioral training reduce postprostatectomy incontinence?. Nat Clin Pract Urol. Jun. 2006;3(6):302-3. Not eligible target population. [pmid: 16763638].
2266 Miles-Thomas J, Gearhart JP, Gearhart SL. An initial evaluation of pelvic floor function and quality of life of bladder exstrophy patients after ureterosigmoidostomy. J Gastrointest Surg. Apr. 2006;10(4):473-7. Not eligible target population. [pmid: 16627210].
2267 Millard RJ, Halaska M. Efficacy of solifenacin in patients with severe symptoms of overactive bladder: a pooled analysis. Curr Med Res Opin. Jan. 2006;22(1):41-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16393429].
2268 Miller DC, Sanda MG, Dunn RL, et al. Long-term outcomes among localized prostate cancer survivors: health-related quality-of-life changes after radical prostatectomy, external radiation, and brachytherapy. J Clin Oncol. Apr. 20. 2005;23(12):2772-80. Not eligible target population. [pmid: 15837992].
2269 Miller JM, Sampselle C, Ashton-Miller J, et al. Clarification and confirmation of the Knack maneuver: the effect of volitional pelvic floor muscle contraction to preempt expected stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2008;19(6):773-82. No primary results. [pmid: 18204797].
2270 Miller KC, Mack GW, Knight KL, et al. Reflex inhibition of electrically induced muscle cramps in hypohydrated humans. Med Sci Sports Exerc. May. 2010;42(5):953-61. Not eligible target population. [pmid: 19997012].
2271 Miller NL, Bissonette EA, Bahnson R, et al. Impact of a novel neoadjuvant and adjuvant hormone-deprivation approach on quality of life, voiding function, and sexual function after prostate brachytherapy. Cancer. Mar. 1. 2003;97(5):1203-10. Not eligible target population. [pmid: 12599226].
2272 Miller YD, Brown WJ, Smith N, et al. Managing urinary incontinence across the lifespan. Int J Behav Med. 2003;10(2):143-61. Not eligible exposure. [pmid: 12763707].
2273 Mills R, Persad R, Handley Ashken M. Long-term follow-up results with the Stamey operation for stress incontinence of urine. Br J Urol. Jan. 1996;77(1):86-8. Not eligible exposure. [pmid: 8653322].
2274 Milne J. The impact of information on health behaviors of older adults with urinary incontinence. Clin Nurs Res. May. 2000;9(2):161-76. Not eligible outcomes. [pmid: 12162240].
2275 Milne JL, Moore KN. Factors impacting self-care for urinary incontinence. Urol Nurs. Feb. 2006;26(1):41-51. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16562385].
2276 Milne JL, Spiers JA, Moore KN. Men’s experiences following laparoscopic radical prostatectomy: a qualitative descriptive study. Int J Nurs Stud. May. 2008;45(5):765-74. Not eligible target population. [pmid: 17482192].
2277 Milsom I. The prevalence of urinary incontinence. Acta Obstet Gynecol Scand. Dec. 2000;79(12):1056-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11130087].
2278 Milsom I, Abrams P, Cardozo L, et al. How widespread are the symptoms of an overactive bladder and how are they managed? A population-based prevalence study. BJU Int. Jun. 2001;87(9):760-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11412210].
2279 Minaglia S, Ozel B, Bizhang R, et al. Increased prevalence of interstitial cystitis in women with detrusor overactivity refractory to anticholinergic therapy. Urology. Oct. 2005;66(4):702-6. Not eligible case series. [pmid: 16230120].
2280 Minardi D, Piloni V, Amadi A, et al. Correlation between urodynamics and perineal ultrasound in female patients with urinary incontinence. Neurourol Urodyn. 2007;26(2):176-82. discussion 83–4. Not eligible outcomes. [pmid: 17016799].
2281 Minassian VM, Ross S, Lovatsis D, et al. Randomized Trial of Oxybutinin Ir Versus Oxybutinin Xl in the Management of Overactive Bladder in Women over the Age of 65. Paper presented at: 31st Annual Meeting of the International Urogynecological Association, Athens Hilton Hotel. Athens (Greece). 6–9 Sep 2006. Not eligible level of evidence.
2282 Mitropoulos D, Papadoukakis S, Zervas A, et al. Efficacy of tolterodine in preventing urge incontinence immediately after prostatectomy. Int Urol Nephrol. 2006;38(2):263-8. Not eligible target population. [pmid: 16868694].
2283 Mitsui T, Tanaka H, Moriya K, et al. Outcomes of lower urinary and bowel function in meningomyelocele patients with augmentation enterocystoplasty. Spinal Cord. Jun. 2008;46(6):432-7. Not eligible target population. [pmid: 18317489].
2284 Mitterberger M, Marksteiner R, Margreiter E, et al. Autologous myoblasts and fibroblasts for female stress incontinence: a 1-year follow-up in 123 patients. BJU Int. Nov. 2007;100(5):1081-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17760890].
2285 Mitterberger M, Marksteiner R, Margreiter E, et al. Myoblast and fibroblast therapy for post-prostatectomy urinary incontinence: 1-year followup of 63 patients. J Urol. Jan. 2008;179(1):226-31. Not eligible target population. [pmid: 18001790].
2286 Mitterberger M, Pinggera GM, Marksteiner R, et al. Adult stem cell therapy of female stress urinary incontinence. Eur Urol. Jan. 2008;53(1):169-75. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17683852].
2287 Mittmann N, Trakas K, Risebrough N, et al. Utility scores for chronic conditions in a community-dwelling population. Pharmacoeconomics. Apr. 1999;15(4):369-76. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10537955].
2288 Mizunaga M, Miyata M, Kaneko S, et al. Intravesical instillation of oxybutynin hydrochloride therapy for patients with a neuropathic bladder. Paraplegia. Jan. 1994;32(1):25-9. Not eligible exposure. [pmid: 8015832].
2289 Mo F, Choi BC, Li FC, et al. Using Health Utility Index (HUI) for measuring the impact on health-related quality of Life (HRQL) among individuals with chronic diseases. ScientificWorldJournal. Aug. 27. 2004;4:746-57. Not eligible target population. [pmid: 15349514].
2290 Moghimi K, Valbo A. Genital prolapse: a follow-up study assessing subjective and objective results five years or more after surgical intervention. Eur J Obstet Gynecol Reprod Biol. Jun. 1. 2005;120(2):198-201. Not eligible exposure. [pmid: 15925052].
2291 Mogielnicki RP, Nelson WA, Dulac J. A study of the dying process in elderly hospitalized males. J Cancer Educ. 1990;5(2):135-45. Not eligible target population. [pmid: 2206934].
2292 Moisey CU, Stephenson TP, Brendler CB. The urodynamic and subjective results of treatment of detrusor instability with oxybutynin chloride. Br J Urol. Dec. 1980;52(6):472-5. Not eligible target population. [pmid: 7006730].
2293 Mok VC, Lam WW, Fan YH, et al. Effects of statins on the progression of cerebral white matter lesion: Post hoc analysis of the ROCAS (Regression of Cerebral Artery Stenosis) study. J Neurol. May. 2009;256(5):750-7. Not eligible target population. [pmid: 19252811].
2294 Mokrzycki ML, Hampton BS. Vesicouterine fistula presenting with urinary incontinence after primary cesarean section: a case report. Journal of Reproductive Medicine. Dec. 2007;52(12):1107-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18210902].
2295 Molander U. Urinary incontinence and related urogenital symptoms in elderly women. Acta Obstet Gynecol Scand Suppl. 1993;158:1-22. Not eligible exposure. [pmid: 8396841].
2296 Molander U, Arvidsson L, Milsom I, et al. A longitudinal cohort study of elderly women with urinary tract infections. Maturitas. Feb. 15. 2000;34(2):127-31. Not eligible target population. [pmid: 10714907].
2297 Molander U, Milsom I, Ekelund P, et al. An epidemiological study of urinary incontinence and related urogenital symptoms in elderly women. Maturitas. Apr. 1990;12(1):51-60. Not eligible target population. [pmid: 2333037].
2298 Mold JW. Pharmacotherapy of urinary incontinence. Am Fam Physician. Aug. 1996;54(2):673-80. 83. 5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8701844].
2299 Moller LA, Lose G, Jorgensen T. The prevalence and bothersomeness of lower urinary tract symptoms in women 40–60 years of age. Acta Obstet Gynecol Scand. Apr. 2000;79(4):298-305. Not eligible target population. [pmid: 10746846].
2300 Monfort-Panego M, Vera-Garcia FJ, Sanchez-Zuriaga D, et al. Electromyographic studies in abdominal exercises: a literature synthesis. J Manipulative Physiol Ther. Mar–Apr. 2009;32(3):232-44. Not eligible review. [pmid: 19362234].
2301 Monga AK, Robinson D, Stanton SL. Periurethral collagen injections for genuine stress incontinence: a 2-year follow-up. Br J Urol. Aug. 1995;76(2):156-60. Not eligible exposure. [pmid: 7663903].
2302 Montague DK, Angermeier KW, Paolone DR. Long-term continence and patient satisfaction after artificial sphincter implantation for urinary incontinence after prostatectomy. J Urol. Aug. 2001;166(2):547-9. Not eligible target population. [pmid: 11458065].
2303 Monz B, Chartier-Kastler E, Hampel C, et al. Patient characteristics associated with quality of life in European women seeking treatment for urinary incontinence: results from PURE. Eur Urol. Apr. 2007;51(4):1073-81. discussion 81–2. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17081676].
2304 Monz B, Pons ME, Hampel C, et al. Patient-reported impact of urinary incontinence--results from treatment seeking women in 14 European countries. Maturitas. Nov. 30. 2005;52(Suppl 2):S24-34. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16297579].
2305 Moore AA, Siu A, Partridge JM, et al. A randomized trial of office-based screening for common problems in older persons. Am J Med. Apr. 1997;102(4):371-8. Not eligible target population. [pmid: 9217619].
2306 Moore K, Allen M, Voaklander DC. Pad tests and self-reports of continence in men awaiting radical prostatectomy: establishing baseline norms for males. Neurourol Urodyn. 2004;23(7):623-6. Not eligible target population. [pmid: 15382185].
2307 Moore K, Griffiths D, Latimer G, et al. Twenty four-hour monitoring of incontinence and bladder function in a community hospital. J ET Nurs. Jul–Aug. 1993;20(4):163-8. Not eligible target population. [pmid: 8343556].
2308 Moore KH, Foote A, Burton G, et al. An open study of the bladder neck support prosthesis in genuine stress incontinence. Br J Obstet Gynaecol. Jan. 1999;106(1):42-9. Not eligible exposure. [pmid: 10426258].
2309 Moore KH, Foote A, Siva S, et al. The use of the bladder neck support prosthesis in combined genuine stress incontinence and detrusor instability. Aust N Z J Obstet Gynaecol. Nov. 1997;37(4):440-5. Not eligible exposure. [pmid: 9429710].
2310 Moore KH, Goldstein M, Hay D. The treatment of detrusor instability in postmenopausal women with oxybutynin chloride: a double blind placebo controlled study. Br J Obstet Gynaecol. Nov. 1990;97(11):1063-4. Comment. [pmid: 2082973].
2311 Moore KN, Estey A. The early post-operative concerns of men after radical prostatectomy. J Adv Nurs. May. 1999;29(5):1121-9. Not eligible target population. [pmid: 10320495].
2312 Moore KN, Griffiths D, Hughton A. Urinary incontinence after radical prostatectomy: a randomized controlled trial comparing pelvic muscle exercises with or without electrical stimulation. BJU Int. Jan. 1999;83(1):57-65. Not eligible target population. [pmid: 10233453].
2313 Moore KN, Schieman S, Ackerman T, et al. Assessing comfort, safety, and patient satisfaction with three commonly used penile compression devices. Urology. Jan. 2004;63(1):150-4. Not eligible target population. [pmid: 14751370].
2314 Moore KN, Truong V, Estey E, et al. Urinary incontinence after radical prostatectomy: can men at risk be identified preoperatively?. J Wound Ostomy Continence Nurs. May–Jun. 2007;34(3):270-9. quiz 80–1. Not eligible target population. [pmid: 17505246].
2315 Moore KN, Valiquette L, Chetner MP, et al. Return to continence after radical retropubic prostatectomy: a randomized trial of verbal and written instructions versus therapist-directed pelvic floor muscle therapy. Urology. Dec. 2008;72(6):1280-6. Not eligible target population. [pmid: 18384853].
2316 Moran F, Bradley JM, Boyle L, et al. Incontinence in adult females with cystic fibrosis: a Northern Ireland survey. Int J Clin Pract. Apr. 2003;57(3):182-3. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12723720].
2317 Morell JD, Morales A. Assessment of long-term patient satisfaction after vesical neck suspension for stress urinary incontinence. Can J Urol. Aug. 2001;8(4):1323-5. Not eligible exposure. [pmid: 11564275].
2318 Morgan C, Endozoa N, Paradiso C, et al. Enhanced toileting program decreases incontinence in long term care. Jt Comm J Qual Patient Saf. Apr. 2008;34(4):206-8. Not eligible target population. [pmid: 18468358].
2319 Morgan DJ, Blackburn M, Bax M. Adults with spina bifida and/or hydrocephalus. Postgrad Med J. Jan. 1995;71(831):17-21. Not eligible target population. [pmid: 7708585].
2320 Morgan DM, Dunn RL, Fenner DE, et al. Comparative analysis of urinary incontinence severity after autologous fascia pubovaginal sling, pubovaginal sling and tension-free vaginal tape. J Urol. Feb. 2007;177(2):604-8. discussion 8–9. Not eligible exposure. [pmid: 17222642].
2321 Morgan DM, Dunn RL, Stoffel JT, et al. Are persistent or recurrent symptoms of urinary incontinence after surgery associated with adverse effects on sexual activity or function?. Int Urogynecol J Pelvic Floor Dysfunct. Apr. 2008;19(4):509-15. Not eligible exposure. [pmid: 17938843].
2322 Morgan TO Jr, Westney OL, McGuire EJ. Pubovaginal sling: 4-YEAR outcome analysis and quality of life assessment. J Urol. Jun. 2000;163(6):1845-8. Not eligible exposure. [pmid: 10799196].
2323 Mori K. Management of idiopathic normal-pressure hydrocephalus: a multiinstitutional study conducted in Japan. J Neurosurg. Dec. 2001;95(6):970-3. Not eligible target population. [pmid: 11765841].
2324 Morin M, Dumoulin C, Bourbonnais D, et al. Pelvic floor maximal strength using vaginal digital assessment compared to dynamometric measurements. Neurourology and urodynamics. 2004:336-41. Not eligible exposure. [pmid: 15227651].
2325 Morishita L, Uman GC, Pierson CA. Education on adult urinary incontinence in nursing school curricula: can it be done in two hours?. Nurs Outlook. May–Jun. 1994;42(3):123-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8084761].
2326 Mørkved S, Bø K. Effect of postpartum pelvic floor muscle training in prevention and treatment of urinary incontinence: a one-year follow up. BJOG : an international journal of obstetrics and gynaecology. 2000:1022-8. Not eligible target population. [pmid: 10955436].
2327 Morkved S, Bo K, Schei B, et al. Pelvic floor muscle training during pregnancy to prevent urinary incontinence: a single-blind randomized controlled trial. Obstet Gynecol. Feb. 2003;101(2):313-9. Not eligible target population. [pmid: 12576255].
2328 Morkved S, Salvesen KA, Bo K, et al. Pelvic floor muscle strength and thickness in continent and incontinent nulliparous pregnant women. Int Urogynecol J Pelvic Floor Dysfunct. Nov–Dec. 2004;15(6):384-9. discussion 90. Not eligible target population. [pmid: 15278255].
2329 Morley R. The future of SUI management ... a shift in emphasis?. Health Serv J. Sep. 16. 2004;114(5923). suppl 14–5. following 54. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15503910].
2330 Morrill M, Lukacz ES, Lawrence JM, et al. Seeking healthcare for pelvic floor disorders: a population-based study. Am J Obstet Gynecol. Jul. 2007;197(1):86 e1-6. Not eligible outcomes. [pmid: 17618770].
2331 Morris AR, Ho MT, Lapsley H, et al. Costs of managing urinary and faecal incontinence in a sub-acute care facility: a “bottom-up” approach. Neurourol Urodyn. 2005;24(1):56-62. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15573385].
2332 Morrison A, Levy R. Fraction of nursing home admissions attributable to urinary incontinence. Value Health. Jul–Aug. 2006;9(4):272-4. Not eligible target population. [pmid: 16903997].
2333 Morrison LM, Glen ES, Cherry LC, et al. The open access Continence Resource Centre for Greater Glasgow Health Board. Br J Urol. Oct. 1992;70(4):395-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 1450847].
2334 Morrow L. SIGN guidelines on managing urinary incontinence. Nurs Times. May. 3–9. 2005;101(18):53-4. guidelines. [pmid: 15892507].
2335 Mortensen N, Humphreys MS. The anal continence plug: a disposable device for patients with anorectal incontinence. Lancet. 1991;(8762):295-7. not eligible exposure. [pmid: 1677121].
2336 Moseley CB. The impact of federal regulations on urethral catheterization in Virginia nursing homes. Am J Med Qual. Winter. 1996;11(4):222-6. Not eligible target population. [pmid: 8972940].
2337 Moskowitz MO, Byrne DS, Callahan HJ, et al. Decreased expression of a glycoprotein component of bladder surface mucin (GP1) in interstitial cystitis. J Urol. Feb. 1994;151(2):343-5. Not eligible outcomes. [pmid: 8283520].
2338 Mostafa A, Hassafa Z, Abdel-Fattah M. Can the patient global impression of improvement questionnaire predict the results of long quality of life and sexual function questionnaires?. Paper presented at: Neurourology and Urodynamics, 2010; Joint Meeting of the International Continence Society and the International Urogynecological Association. Toronto, Canada. 23–27 August 2010. Not eligible exposure.
2339 Mottet N, Boyer C, Chartier-Kastler E, et al. Artificial urinary sphincter AMS 800 for urinary incontinence after radical prostatectomy: the French experience. Urol Int. 1998;60(Suppl 2):25-9. discussion 35. Not eligible target population. [pmid: 9607555].
2340 Mouriquand PD, Mollard P. Management of urinary incontinence in neurogenic bladder. Scand J Urol Nephrol Suppl. 1992;141:28-36. discussion 7–8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 1609250].
2341 Mouritsen L, Bach P. Ultrasonic evaluation of bladder neck position and mobility: the influence of urethral catheter, bladder volume, and body position. Neurourol Urodyn. 1994;13(6):637-46. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7697055].
2342 Mouritsen L, Schiotz HA. Pro et contra pelvic floor exercises for female stress urinary incontinence. Acta Obstet Gynecol Scand. Dec. 2000;79(12):1043-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11130084].
2343 Mouritsen L, Strandberg C, Jensen AR, et al. Inter- and intra-observer variation of colpo-cysto-urethrography diagnoses. Acta Obstet Gynecol Scand. Apr. 1993;72(3):200-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8385856].
2344 Mourtzinos A, Maher MG, Raz S, et al. Spiral sling salvage anti-incontinence surgery for women with refractory stress urinary incontinence: surgical outcome and satisfaction determined by patient-driven questionnaires. Urology. Nov. 2008;72(5):1044-8. discussion 8–50. Not eligible exposure. [pmid: 18804264].
2345 Movig KL, Leufkens HG, Belitser SV, et al. Selective serotonin reuptake inhibitor-induced urinary incontinence. Pharmacoepidemiol Drug Saf. Jun. 2002;11(4):271-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12138594].
2346 Mozes B, Shmueli A. Underutilization of health services among patients with urinary symptoms: results of a population-based survey in Israel. Prostate. Dec. 1. 1997;33(4):246-51. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9397196].
2347 Mueller C, Cain H. Comprehensive management of urinary incontinence through quality improvement efforts. Geriatr Nurs. Mar–Apr. 2002;23(2):82-7. no primary result. [pmid: 11956520].
2348 Mueller V. A shared community-based practice: an alternative model for WOC nursing practice. J Wound Ostomy Continence Nurs. Mar. 1998;25(2):84-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9592470].
2349 Mukerji G, Yiangou Y, Grogono J, et al. Localization of M2 and M3 muscarinic receptors in human bladder disorders and their clinical correlations. J Urol. Jul. 2006;176(1):367-73. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16753445].
2350 Mukherjee K, Constantine G. Urinary stress incontinence in obese women: tension-free vaginal tape is the answer. BJU Int. Dec. 2001;88(9):881-3. Not eligible exposure. [pmid: 11851607].
2351 Muller N. What Americans understand and how they are affected by bladder control problems: highlights of recent nationwide consumer research. Urol Nurs. Apr. 2005;25(2):109-15. not eligible outcomes. [pmid: 15900979].
2352 Mullins CD, Subak LL. New perspectives on overactive bladder: quality of life impact, medication persistency, and treatment costs. Am J Manag Care. Jul. 2005;11(4 Suppl):S101-2. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16161382].
2353 Muncie HL Jr, Warren JW. Reasons for replacement of long-term urethral catheters: implications for randomized trials. J Urol. Mar. 1990;143(3):507-9. Not eligible target population. [pmid: 2406463].
2354 Munding M, Wessells H, Thornberry B, et al. Use of tolterodine in children with dysfunctional voiding: an initial report. J Urol. Mar. 2001;165(3):926-8. Not eligible target population. [pmid: 11176516].
2355 Munir N, Bunce C, Gelister J, et al. Outcome following TVT sling procedure: a comparison of outcome recorded by surgeons to that reported by their patients at a London district general hospital. Eur Urol. May. 2005;47(5):635-40. discussion 40. Not eligible exposure. [pmid: 15826755].
2356 Murphy DJ, Macleod M, Bahl R, et al. A randomised controlled trial of routine versus restrictive use of episiotomy at operative vaginal delivery: a multicentre pilot study. BJOG. Dec. 2008;115(13):1695-702. discussion 702–3. Not eligible exposure. [pmid: 19035944].
2357 Murphy M, Culligan PJ, Arce CM, et al. Is the cough-stress test necessary when placing the tension-free vaginal tape?. Obstet Gynecol. Feb. 2005;105(2):319-24. Not eligible exposure. [pmid: 15684159].
2358 Murphy M, Culligan PJ, Arce CM, et al. Construct validity of the incontinence severity index. Neurourol Urodyn. 2006;25(5):418-23. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16652379].
2359 Murphy M, van Raalte H, Mercurio E, et al. Incontinence-related quality of life and sexual function following the tension-free vaginal tape versus the “inside-out” tension-free vaginal tape obturator. Int Urogynecol J Pelvic Floor Dysfunct. Apr. 2008;19(4):481-7. Not eligible exposure. [pmid: 17940718].
2360 Muscatello DJ, Rissel C, Szonyi G. Urinary symptoms and incontinence in an urban community: prevalence and associated factors in older men and women. Intern Med J. Apr. 2001;31(3):151-60. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11478344].
2361 Mushkat Y, Bukovsky I, Langer R. Female urinary stress incontinence--does it have familial prevalence?. Am J Obstet Gynecol. Feb. 1996;174(2):617-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8623794].
2362 Muskat Y, Bukovsky I, Schneider D, et al. The use of scopolamine in the treatment of detrusor instability. J Urol. Dec. 1996;156(6):1989-90. Not eligible exposure. [pmid: 8911372].
2363 Musselman DM, Ford AP, Gennevois DJ, et al. A randomized crossover study to evaluate Ro 115-1240, a selective alpha1A/1L-adrenoceptor partial agonist in women with stress urinary incontinence. BJU Int. Jan. 2004;93(1):78-83. Not eligible exposure. [pmid: 14678373].
2364 Myers DL, Peipert JF, Rosenblatt PL, et al. Patient satisfaction with laparoscopic Burch retropubic urethropexy. J Reprod Med. Nov. 2000;45(11):939-43. Not eligible exposure. [pmid: 11127109].
2365 Myint PK, Vowler SL, Redmayne O, et al. Cognition, continence and transfer status at the time of discharge from an acute hospital setting and their associations with an unfavourable discharge outcome after stroke. Gerontology. 2008;54(4):202-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18408357].
2366 Nager C, Stanton S. Can HRT help incontinence?. Community Nurse. May. 1997;3(4):32-3. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9451143].
2367 Nager CW, FitzGerald M, Kraus SR, et al. Urodynamic measures do not predict stress continence outcomes after surgery for stress urinary incontinence in selected women. J Urol. Apr. 2008;179(4):1470-4. Not eligible exposure. [pmid: 18295276].
2368 Nager CW, Schulz JA, Stanton SL, et al. Correlation of urethral closure pressure, leak-point pressure and incontinence severity measures. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(6):395-400. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11795644].
2369 Naidu A, Lim YN, Barry C, et al. Transobturator tape for stress incontinence: the North Queensland experience. Aust N Z J Obstet Gynaecol. Oct. 2005;45(5):446-9. Not eligible exposure. [pmid: 16171486].
2370 Namiki S, Ishidoya S, Saito S, et al. Natural history of voiding function after radical retropubic prostatectomy. Urology. Jul. 2006;68(1):142-7. Not eligible target population. [pmid: 16777193].
2371 Namiki S, Kuwahara M, Ioritani N, et al. An evaluation of urinary function after radical prostatectomy in Japanese men: concordance with definitions of urinary continence. BJU Int. Mar. 2005;95(4):530-3. Not eligible target population. [pmid: 15705074].
2372 Namiki S, Saito S, Ishidoya S, et al. Adverse effect of radical prostatectomy on nocturia and voiding frequency symptoms. Urology. Jul. 2005;66(1):147-51. Not eligible target population. [pmid: 15992905].
2373 Namiki S, Saito S, Nakagawa H, et al. Impact of unilateral sural nerve graft on recovery of potency and continence following radical prostatectomy: 3-year longitudinal study. J Urol. Jul. 2007;178(1):212-6. discussion 6. Not eligible target population. [pmid: 17499797].
2374 Namiki S, Takegami M, Kakehi Y, et al. Analysis linking UCLA PCI with Expanded Prostate Cancer Index Composite: an evaluation of health related quality of life in Japanese men with localized prostate cancer. J Urol. Aug. 2007;178(2):473-7. discussion 7. Not eligible target population. [pmid: 17561164].
2375 Narayanan S, Cerulli A, Kahler KH, et al. Is drug therapy for urinary incontinence used optimally in long-term care facilities?. Journal of the American Medical Directors Association. Feb. 2007;8(2):98-104. Not eligible target population. [pmid: 17289539].
2376 Natsume O, Kondo H, Cho M, et al. The impact of radical prostatectomy on patient well-being: a prospective urodynamic study focused on detrusor function. Hinyokika Kiyo. Jan. 2004;50(1):1-6. Not eligible target population. [pmid: 15032007].
2377 Nauth MA, Funfgeld C. Correction of cystocele and stress incontinence with anterior transobturator mesh. Eur J Obstet Gynecol Reprod Biol. Feb. 2008;136(2):249-53. Not eligible exposure. [pmid: 17669580].
2378 Naylor JR, Mulley GP. Commodes: inconvenient conveniences. BMJ. Nov. 13. 1993;307(6914):1258-60. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8281060].
2379 Nazarko L. A new perspective on an old problem. Nurs Times. Jul 26–Aug 1. 2001;97(30):52-3. no primary result. [pmid: 11957958].
2380 Nazarko L. Managing bladder dysfunction using intermittent self-catheterization. Br J Nurs. Jan 22–Feb 11. 2009;18(2):110-5. Not eligible target population. [pmid: 19270610].
2381 Nazemi TM, Rapp DE, Govier FE, et al. Cadaveric fascial sling with bone anchors: minimum of 24 months of follow-up. Urology. May. 2008;71(5):834-8. Not eligible exposure. [pmid: 18372032].
2382 Nazemi TM, Yamada B, Govier FE, et al. Minimum 24-month followup of the sling for the treatment of stress urinary incontinence. J Urol. Feb. 2008;179(2):596-9. Not eligible exposure. [pmid: 18082220].
2383 Neal R, Linnane J. Improving access to continence services: action in Walsall. Br J Community Nurs. Nov. 70. 2002;7(11):567-3. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12447118].
2384 Nemett DR, Fivush BA, Mathews R, et al. A randomized controlled trial of the effectiveness of osteopathy-based manual physical therapy in treating pediatric dysfunctional voiding. J Pediatr Urol. Apr. 2008;4(2):100-6. Not eligible target population. [pmid: 18631903].
2385 Neumann PB, Grimmer KA, Grant RE, et al. Physiotherapy for female stress urinary incontinence: a multicentre observational study. Aust N Z J Obstet Gynaecol. Jun. 2005;45(3):226-32. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15904449].
2386 Neumann PB, Grimmer KA, Grant RE, et al. The costs and benefits of physiotherapy as first-line treatment for female stress urinary incontinence. Aust N Z J Public Health. Oct. 2005;29(5):416-21. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16255442].
2387 Newman DK. New treatment options for overactive bladder and incontinence. Director. Summer. 2002;10(3):74-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12116753].
2388 Newman DK. Urinary incontinence in long-term care facilities: current clinical practice. Director. Winter. 2004;12(1):30-3. quiz 4. Not eligible target population. [pmid: 19178115].
2389 Newman DK. Report of a mail survey of women with bladder control disorders. Urol Nurs. Dec. 2004;24(6):499-507. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15658736].
2390 Newman DK. Resolution for all year. Interview by Barbara Zeiger. Ostomy Wound Manage. Jan. 2005;51(1):14-6. [pmid: 15706701]. Did not provide comparative assessment of the outcomes among different treatments for female UI.
2391 Newman DK. The MATRIX study: evaluating the data in older adults. Director. Spring. 2008;16(2):21-4. Comment. [pmid: 19343880].
2392 Newton M, Kosier JH, Smith D. Treatments for overactive bladder. Urol Nurs. Aug. 2000;20(4):267-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11998091].
2393 Ney P, Pandita RK, Newgreen DT, et al. Pharmacological characterization of a novel investigational antimuscarinic drug, fesoterodine, in vitro and in vivo. BJU Int. Apr. 2008;101(8):1036-42. Not eligible target population. [pmid: 18279452].
2394 Ngninkeu BN, van Heugen G, di Gregorio M, et al. Laparoscopic artificial urinary sphincter in women for type III incontinence: preliminary results. Eur Urol. Jun. 2005;47(6):793-7. discussion 7. Not eligible exposure. [pmid: 15925075].
2395 Nguyen JK, Glowacki CA, Bhatia NN. Survey of voiding dysfunction and urinary retention after anti-incontinence procedures. Obstet Gynecol. Dec. 2001;98(6):1011-7. Not eligible exposure. [pmid: 11755546].
2396 Nguyen JN. Tape mobilization for urinary retention after tension-free vaginal tape procedures. Urology. Sep. 2005;66(3):523-6. Not eligible exposure. [pmid: 16140070].
2397 Nichols CM, Lamb EH, Ramakrishnan V. Differences in outcomes after third- versus fourth-degree perineal laceration repair: a prospective study. Am J Obstet Gynecol. Aug. 2005;193(2):530-4. discussion 4–6. Not eligible Case-series. [pmid: 16098885].
2398 Nicol D, Ward J, McMullin R, et al. Urological training in Australasia: perceptions of recent fellows and current trainees. Aust N Z J Surg. Apr. 1995;65(4):278-83. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7717949].
2399 Nigam AK, Otite U, Badenoch DF. Endoscopic bladder neck suspension revisited: long-term results of Stamey and Gittes procedures. Eur Urol. Dec. 2000;38(6):677-80. Not eligible exposure. [pmid: 11111183].
2400 Nijman RJ, Borgstein NG, Ellsworth P, et al. Tolterodine treatment for children with symptoms of urinary urge incontinence suggestive of detrusor overactivity: results from 2 randomized, placebo controlled trials. J Urol. Apr. 2005;173(4):1334-9. Not eligible target population. [pmid: 15758796].
2401 Nijman RJ, Borgstein NG, Ellsworth P, et al. Long-term tolerability of tolterodine extended release in children 5–11 years of age: results from a 12-month, open-label study. European urology. Nov. 2007;52(5):1511-6. Not eligible target population. [pmid: 17574729].
2402 Nikoletti S, Young J, King M. Evaluation of an electronic monitoring device for urinary incontinence in elderly patients in an acute care setting. J Wound Ostomy Continence Nurs. May–Jun. 2004;31(3):138-49. Not eligible target population. [pmid: 15867743].
2403 Nilsson CG, Falconer C, Rezapour M. Seven-year follow-up of the tension-free vaginal tape procedure for treatment of urinary incontinence. Obstet Gynecol. Dec. 2004;104(6):1259-62. Not eligible exposure. [pmid: 15572486].
2404 Nilsson CG, Palva K, Rezapour M, et al. Eleven years prospective follow-up of the tension-free vaginal tape procedure for treatment of stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2008;19(8):1043-7. Not eligible exposure. [pmid: 18535753].
2405 Ninan GK, Jutley RS, Eremin O. Urinary cytokines as markers of reflux nephropathy. J Urol. Nov. 1999;162(5):1739-42. Not eligible outcomes. [pmid: 10524926].
2406 Nissenkorn I, De Jong PR. A novel surgical technique for implanting a new electrostimulation system for treating female overactive bladder: a preliminary report. BJU Int. Jun. 2005;95(9):1253-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15892811].
2407 Nissenkorn I, Shalev M, Radziszewski P, et al. Patient-adjusted intermittent electrostimulation for treating stress and urge urinary incontinence. BJU Int. Jul. 2004;94(1):105-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15217441].
2408 Nitti VW, Adler H, Combs AJ. The role of urodynamics in the evaluation of voiding dysfunction in men after cerebrovascular accident. J Urol. Jan. 1996;155(1):263-6. Not eligible target population. [pmid: 7490851].
2409 Nitti VW, Dmochowski R, Appell RA, et al. Efficacy and tolerability of tolterodine extended-release in continent patients with overactive bladder and nocturia. BJU Int. Jun. 2006;97(6):1262-6. Not eligible target population. [pmid: 16686723].
2410 Nitz NM, Jumadilova Z, Darkow T, et al. Medical costs after initiation of drug treatment for overactive bladder: effects of selection bias on cost estimates. Am J Manag Care. Jul. 2005;11(4 Suppl):S130-9. Not eligible outcomes. [pmid: 16161386].
2411 Nix DH. Validity and reliability of the Perineal Assessment Tool. Ostomy Wound Manage. Feb. 2002;48(2):43-6. 8. 9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15382413].
2412 Nixon E. Continence. Easing the social stress. Nurs Times. Dec. 13–19. 1995;91(50):60. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8559688].
2413 Noe L, Sneeringer R, Patel B, et al. The implications of poor medication persistence with treatment for overactive bladder. Manag Care Interface. Nov. 2004;17(11):54-60. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15573804].
2414 Noguchi M, Kakuma T, Suekane S, et al. A randomized clinical trial of suspension technique for improving early recovery of urinary continence after radical retropubic prostatectomy. BJU Int. Sep. 2008;102(8):958-63. not eligible target population. [pmid: 18485031].
2415 Noguchi M, Kakuma T, Tomiyasu K, et al. Effect of an extract of Ganoderma lucidum in men with lower urinary tract symptoms: a double-blind, placebo-controlled randomized and dose-ranging study. Asian J Androl. Jul. 2008;10(4):651-8. Not eligible target population. [pmid: 18097503].
2416 Noonan VK, Kopec JA, Zhang H, et al. Impact of associated conditions resulting from spinal cord injury on health status and quality of life in people with traumatic central cord syndrome. Arch Phys Med Rehabil. Jun. 2008;89(6):1074-82. Not eligible target population. [pmid: 18503802].
2417 Nordstrom G, Nyman CR, Theorell T. Psychosocial adjustment and general state of health in patients with ileal conduit urinary diversion. Scand J Urol Nephrol. 1992;26(2):139-47. Not eligible exposure. [pmid: 1626203].
2418 North A. Continence. The client’s view. Nurs Times. Jan 26-Feb 1. 1994;90(4):80-2. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8108267].
2419 North BB. A disposable adhesive patch for stress urinary incontinence. Fam Med. Apr. 1998;30(4):258-64. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9568494].
2420 Norton C. Providing appropriate services for continence: an overview. Nurs Stand. Jun. 26. 1996;10(40):41-5. Not eligible exposure. [pmid: 8718019].
2421 Norton P, Karram M, Wall LL, et al. Randomized double-blind trial of terodiline in the treatment of urge incontinence in women. Obstet Gynecol. Sep. 1994;84(3):386-91. Not eligible exposure. [pmid: 8058236].
2422 Nosseir M, Hinkel A, Pannek J. Clinical usefulness of urodynamic assessment for maintenance of bladder function in patients with spinal cord injury. Neurourol Urodyn. 2007;26(2):228-33. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16998859].
2423 Notelovitz M. Estrogen therapy in the management of problems associated with urogenital ageing: a simple diagnostic test and the effect of the route of hormone administration. Maturitas. Dec. 1995;22(Suppl):S31-3. Not eligible outcomes. [pmid: 8775774].
2424 Novara G, Artibani W. Myoblasts and fibroblasts in stress urinary incontinence. Lancet. Jun. 30. 2007;369(9580):2139-40. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17604781].
2425 Novi JM, Mulvihill BH. Surgical intervention for stress urinary incontinence: comparison of midurethral sling procedures. Journal of the American Osteopathic Association. Nov. 2008;108(11):634-8. Not eligible exposure. [pmid: 19011226].
2426 Nygaard I. Physiologic Outcome Measures for Urinary Incontinence. Gastroenterology. 2004;(126):1. Review. [pmid: 14728722].
2427 Nygaard I, Handa VL, Brubaker L, et al. Changes in physical activity after abdominal sacrocolpopexy for advanced pelvic organ prolapse. Am J Obstet Gynecol. May. 2008;198(5):570 e1-5. Not eligible exposure. [pmid: 18455536].
2428 O’Brien B, Bradford J, Gibb H. Nine steps to better nursing management of incontinence. Contemp Nurse. Sep. 1995;4(3):131-8. Comment. [pmid: 8696034].
2429 O’Connell B, Baker L, Munro I. The nature and impact of incontinence in men who have undergone prostate surgery and implications for nursing practice. Contemp Nurse. Feb. 2007;24(1):65-78. Not eligible target population. [pmid: 17348784].
2430 O’Connell B, Day K, Wellman D, et al. Development, implementation, and evaluation of a continence education package in acute and subacute care settings. J Wound Ostomy Continence Nurs. Mar–Apr. 2005;32(2):101-11. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15867700].
2431 O’Connell B, Hanna B, Bailey S, et al. The nature and severity of urinary incontinence in post-natal women. Contemp Nurse. Oct. 2002;13(2–3):158-68. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16116771].
2432 O’Connell B, Wellman D, Baker L, et al. Does a continence educational brochure promote health-seeking behavior?. J Wound Ostomy Continence Nurs. Jul–Aug. 2006;33(4):389-95. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16932121].
2433 O’Connor I. Management of urinary continence problems in an acute general hospital. Int J Nurs Pract. Mar. 1996;2(1):47-9. Not eligible target population. [pmid: 9305033].
2434 O’Connor RC, Kuznetsov DD, Patel RV, et al. Artificial urinary sphincter placement in men after cystectomy with orthotopic ileal neobladder: continence, complications, and quality of life. Urology. Apr. 2002;59(4):542-5. Not eligible target population. [pmid: 11927310].
2435 O’Connor RC, Lyon MB, Guralnick ML, et al. Long-Term Follow-Up of Single Versus Double Cuff Artificial Urinary Sphincter Insertion for Post-Prostatectomy Stress Urinary Incontinence. Paper presented at: 2006 Annual Meeting of the American Urological Association (AUA 2006). Atlanta, Georgia (USA). 20–25 May 2006. Not eligible target population.
2436 O’Connor RC, Lyon MB, Guralnick ML, et al. Long-term follow-up of single versus double cuff artificial urinary sphincter insertion for the treatment of severe postprostatectomy stress urinary incontinence. Urology. Jan. 2008;71(1):90-3. Not eligible target population. [pmid: 18242372].
2437 O’Conor RM, Johannesson M, Hass SL, et al. Urge incontinence. Quality of life and patients’ valuation of symptom reduction. Pharmacoeconomics. Nov. 1998;14(5):531-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10344916].
2438 Odagaki M, Uomori Y, Hosaka H. Current distributions inside 3D abdomen models as obtained by electrical and magnetic stimulations for the treatment of urinary incontinence. 2007. Not eligible outcomes.
2439 O’Dell KK, Jacelon C, Morse AN. ‘I’d rather just go on as I am’--pelvic floor care preferences of frail, elderly women in residential care. Urol Nurs. Feb. 2008;28(1):36-47. Not eligible target population. [pmid: 18335696].
2440 O’Donnell BF, Drachman DA, Barnes HJ, et al. Incontinence and troublesome behaviors predict institutionalization in dementia. J Geriatr Psychiatry Neurol. Jan–Mar. 1992;5(1):45-52. Not eligible target population. [pmid: 1571074].
2441 O’Donnell M, Hunskaar S. Preferences for involvement in treatment decision-making among Norwegian women with urinary incontinence. Acta Obstet Gynecol Scand. 2007;86(11):1370-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17851820].
2442 O’Donnell M, Hunskaar S. Preferences for involvement in treatment decision-making generally and in hormone replacement and urinary incontinence treatment decision-making specifically. Patient Educ Couns. Nov. 2007;68(3):243-51. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17904327].
2443 O’Donnell M, Lose G, Sykes D, et al. Help-seeking behaviour and associated factors among women with urinary incontinence in France, Germany, Spain and the United Kingdom. European urology. discussion 392. Mar. 2005;47(3):385-92. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15716205].
2444 O’Donnell PD. Special considerations in elderly individuals with urinary incontinence. Urology. Feb. 1998;51(2A Suppl):20-3. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9495730].
2445 O’Donnell PD. Behavioral modification for institutionalized individuals with urinary incontinence. Urology. Feb. 1998;51(2A Suppl):40-2. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9495735].
2446 Oefelein MG. Prospective predictors of urinary continence after anatomical radical retropubic prostatectomy: a multivariate analysis. World J Urol. Oct. 2004;22(4):267-71. Not eligible target population. [pmid: 14727136].
2447 Oehlke KJ. New treatment options for overactive bladder. S D J Med. Jun. 2005;58(6):225-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16050656].
2448 O’Flynn KJ, Thomas DG. Intravesical instillation of oxybutynin hydrochloride for detrusor hyper-reflexia. Br J Urol. Nov. 1993;72(5 Pt 1):566-70. Not eligible exposure. [pmid: 10071538].
2449 Ogushi T, Takahashi S. Effect of Chinese herbal medicine on overactive bladder. Hinyokika Kiyo. Dec. 2007;53(12):857-62. Not eligible target population. [pmid: 18203522].
2450 Oh HS, Kim MK, Seo WS. Effectiveness of a behavioral intervention program for urinary incontinence in a community setting. Taehan Kanho Hakhoe Chi. Dec. 2005;35(8):1476-84. Level of evidence. [pmid: 16415628].
2451 Oh SJ, Choo MS, Kim HS, et al. Generic and disease-specific health-related quality of life in women with coital incontinence: a prospective, multicenter study. Gynecol Obstet Invest. 2008;65(1):62-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17851252].
2452 Oh SJ, Hong SK, Son H, et al. Quality of life and disease severity in Korean women with stress urinary incontinence. Urology. Jul. 2005;66(1):69-73. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15992875].
2453 Oh SJ, Ku JH. Does condition-specific quality of life correlate with generic health-related quality of life and objective incontinence severity in women with stress urinary incontinence?. Neurourol Urodyn. 2006;25(4):324-9. discussion 30. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16534817].
2454 Oh SJ, Ku JH. Is a generic quality of life instrument helpful for evaluating women with urinary incontinence?. Qual Life Res. Apr. 2006;15(3):493-501. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16547788].
2455 Oh SJ, Ku JH. Impact of stress urinary incontinence and overactive bladder on micturition patterns and health-related quality of life. Int Urogynecol J Pelvic Floor Dysfunct. Jan. 2007;18(1):65-71. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16575487].
2456 Oh SJ, Ku JH, Choo MS, et al. Health-related quality of life and sexual function in women with stress urinary incontinence and overactive bladder. Int J Urol. Jan. 2008;15(1):62-7. discussion 7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18184175].
2457 Ojanuga D. Preventing birth injury among women in Africa: case studies in northern Nigeria. Am J Orthopsychiatry. Oct. 1991;61(4):533-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 1746628].
2458 Okamura K, Usami T, Nagahama K, et al. “Quality of life” assessment of urination in elderly Japanese men and women with some medical problems using International Prostate Symptom Score and King’s Health Questionnaire. Eur Urol. Apr. 2002;41(4):411-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12074813].
2459 Olah KS, Bridges N, Denning J, et al. The conservative management of patients with symptoms of stress incontinence: a randomized, prospective study comparing weighted vaginal cones and interferential therapy. Am J Obstet Gynecol. Jan. 1990;162(1):87-92. Full text not available. [pmid: 2301521].
2460 O’Leary MP, Gee WF, Holtgrewe HL, et al. American Urological Association Gallup Survey: changes in physician practice patterns, treatment of incontinence and bladder cancer, and impact of managed care. J Urol. 2000. Oct. 1999;164(4):1311-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10992396].
2461 Oliff L. Recent revisions to the State Operations Manual: implications for the management of urinary incontinence. Director. Spring. 2007;15(2):12-6. Comment. [pmid: 19343902].
2462 Oliver H. Contracting for a continence service. Nurs Stand. Jun. 10–16. 1992;6(38):25-7. Comment. [pmid: 1622830].
2463 Olsen AL, Benson JT, McClellan E. Urethral sphincter needle electromyography in women: comparison of periurethral and transvaginal approaches. Neurourol Urodyn. 1998;17(5):531-5. Not eligible exposure. [pmid: 9776016].
2464 Olsson I, Kroon U. A three-year postoperative evaluation of tension-free vaginal tape. Gynecol Obstet Invest. 1999;48(4):267-9. Not eligible exposure. [pmid: 10592431].
2465 Omotosho TB, Hardart A, Rogers RG, et al. Validation of Spanish versions of the Pelvic Floor Distress Inventory (PFDI) and Pelvic Floor Impact Questionnaire (PFIQ): a multicenter validation randomized study. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2009;20(6):623-39. Not eligible exposure. [pmid: 19214363].
2466 Onur R, Singla A, Kobashi KC. Comparison of solvent-dehydrated allograft dermis and autograft rectus fascia for pubovaginal sling: questionnaire-based analysis. Int Urol Nephrol. 2008;40(1):45-9. Not eligible exposure. [pmid: 17610038].
2467 Opsomer RJ. Female urinary incontinence: imaging by or for the urologist. Acta Urol Belg. May. 1995;63(2):31-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7785534].
2468 Ordorica R, Rodriguez AR, Coste-Delvecchio F, et al. Disabling complications with slings for managing female stress urinary incontinence. BJU Int. Aug. 2008;102(3):333-6. Not eligible exposure. [pmid: 18384633].
2469 Orovan WL, Davis IR. Kock to urethra: continent functional bladder replacement. Can J Surg. Apr. 1990;33(2):91-4. Not eligible exposure. [pmid: 2268818].
2470 Orr A, McVean RJ, Webb AK, et al. Questionnaire survey of urinary incontinence in women with cystic fibrosis. BMJ. Jun. 23. 2001;322(7301):1521. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11420273].
2471 Osman T. Stress incontinence surgery for patients presenting with mixed incontinence and a normal cystometrogram. BJU Int. Dec. 2003;92(9):964-8. Not eligible exposure. [pmid: 14632856].
2472 Ostaszkiewicz J. A clinical nursing leadership model for enhancing continence care for older adults in a subacute inpatient care setting. J Wound Ostomy Continence Nurs. Nov–Dec. 2006;33(6):624-9. Not eligible target population. [pmid: 17108772].
2473 Ostergard DR. Lessons from the past: directions for the future. Do new marketed surgical procedures and grafts produce ethical, personal liability, and legal concerns for physicians?. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2007;18(6):591-8. Not eligible exposure. [pmid: 17364134].
2474 O’Sullivan DC, Chilton CP, Munson KW. Should Stamey colposuspension be our primary surgery for stress incontinence?. Br J Urol. Apr. 1995;75(4):457-60. Not eligible exposure. [pmid: 7788256].
2475 O’Sullivan SS, Williams DR, Gallagher DA, et al. Nonmotor symptoms as presenting complaints in Parkinson’s disease: a clinicopathological study. Movement Disorders. Jan. 2008;23(1):101-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17994582].
2476 Ouslander J. Pharmacokinetics and clinical effects of Oxybutynin in geriatric patients. J Urol. 1988;140:47-50. Not eligible outcomes. [pmid: 3379694].
2477 Ouslander JG. Intractable incontinence in the elderly. BJU Int. May. 2000;85(Suppl 3):72-8. discussion 81–2. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11954202].
2478 Ouslander JG. Management of overactive bladder. N Engl J Med. Feb. 19. 2004;350(8):786-99. Review. [pmid: 14973214].
2479 Ouslander JG. Quality improvement initiatives for urinary incontinence in nursing homes. J Am Med Dir Assoc. Mar. 2007;8(3 Suppl):S6-11. Not eligible target population. [pmid: 17336875].
2480 Ouslander JG, Ai-Samarrai N, Schnelle JF. Prompted voiding for nighttime incontinence in nursing homes: is it effective?. Journal of the American Geriatrics Society. 2001:706-9. Not eligible target population. [pmid: 11454107].
2481 Ouslander JG, Greendale GA, Uman G, et al. Effects of oral estrogen and progestin on the lower urinary tract among female nursing home residents. J Am Geriatr Soc. Jun. 2001;49(6):803-7. Not eligible target population. [pmid: 11454122].
2482 Ouslander JG, Griffiths P, McConnell E, et al. Functional Incidental Training: applicability and feasibility in the Veterans Affairs nursing home patient population. J Am Med Dir Assoc. Mar–Apr. 2005;6(2):121-7. Not eligible target population. [pmid: 15871887].
2483 Ouslander JG, Griffiths PC, McConnell E, et al. Functional incidental training: a randomized, controlled, crossover trial in Veterans Affairs nursing homes. J Am Geriatr Soc. Jul. 2005;53(7):1091-100. Not eligible target population. [pmid: 16108924].
2484 Ouslander JG, Schapira M, Schnelle JF. Urine specimen collection from incontinent female nursing home residents. Journal of the American Geriatrics Society. 1995:279-81. Not eligible target population. [pmid: 7884119].
2485 Ouslander JG, Schapira M, Schnelle JF, et al. Does eradicating bacteriuria affect the severity of chronic urinary incontinence in nursing home residents?. Ann Intern Med. May. 15. 1995;122(10):749-54. Not eligible target population. [pmid: 7717597].
2486 Ouslander JG, Schnelle JF, Uman G, et al. Does oxybutynin add to the effectiveness of prompted voiding for urinary incontinence among nursing home residents? A placebo-controlled trial. J Am Geriatr Soc. Jun. 1995;43(6):610-7. Not eligible target population. [pmid: 7775717].
2487 Owan T, Kohra T, Miyara Y, et al. Urination assessment after the removal of bladder catheter using a novel urination chart. Nurs Health Sci. Sep. 2003;5(3):189-97. Not eligible target population. [pmid: 12877720].
2488 Owens DC, Winters JC. Pubovaginal sling using Duraderm graft: intermediate follow-up and patient satisfaction. Neurourol Urodyn. 2004;23(2):115-8. Not eligible exposure. [pmid: 14983421].
2489 Ozerdogan N, Beji NK, Yalcin O. Urinary incontinence: its prevalence, risk factors and effects on the quality of life of women living in a region of Turkey. Gynecol Obstet Invest. 2004;58(3):145-50. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15237249].
2490 Pace G, Vicentini C. Female sexual function evaluation of the tension-free vaginal tape (TVT) and transobturator suburethral tape (TOT) incontinence surgery: results of a prospective study. J Sex Med. Feb. 2008;5(2):387-93. Not eligible exposure. [pmid: 18237371].
2491 Padros J, Peris T, Salva A, et al. Evaluation of a urinary incontinence unit for community-dwelling older adults in Barcelona: implementation and improvement of the perceived impact on daily life, frequency and severity of urinary incontinence. Z Gerontol Geriatr. Aug. 2008;41(4):291-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18695974].
2492 Pagliacci MC, Franceschini M, Di Clemente B, et al. A multicentre follow-up of clinical aspects of traumatic spinal cord injury. Spinal Cord. Jun. 2007;45(6):404-10. Not eligible target population. [pmid: 17102809].
2493 Paick JS, Cho MC, Oh SJ, et al. Influence of self-perceived incontinence severity on quality of life and sexual function in women with urinary incontinence. Neurourol Urodyn. 2007;26(6):828-35. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17335053].
2494 Pakbaz M, Mogren I, Lofgren M. Outcomes of vaginal hysterectomy for uterovaginal prolapse: a population-based, retrospective, cross-sectional study of patient perceptions of results including sexual activity, urinary symptoms, and provided care. BMC Womens Health. 2009;9:9. Not eligible exposure. [pmid: 19379514].
2495 Palese A, Regattin L, Venuti F, et al. Incontinence pad use in patients admitted to medical wards: an Italian multicenter prospective cohort study. J Wound Ostomy Continence Nurs. Nov–Dec. 2007;34(6):649-54. Not eligible target population. [pmid: 18030104].
2496 Palleschi G, Pastore AL, Stocchi F, et al. Correlation between the Overactive Bladder questionnaire (OAB-q) and urodynamic data of Parkinson disease patients affected by neurogenic detrusor overactivity during antimuscarinic treatment. Clin Neuropharmacol. Jul–Aug. 2006;29(4):220-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16855424].
2497 Palmer MH. Nurses’ knowledge and beliefs about continence interventions in long-term care. J Adv Nurs. Jun. 1995;21(6):1065-72. Not eligible target population. [pmid: 7665769].
2498 Palmer MH, Bennett RG, Marks J, et al. Urinary incontinence: a program that works. J Long Term Care Adm. Summer. 1994;22(2):19-25. Not eligible target popluation. [pmid: 10137999].
2499 Palmer MH, Fitzgerald S, Berry SJ, et al. Urinary incontinence in working women: an exploratory study. Women Health. 1999;29(3):67-82. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10466511].
2500 Palmer MH, Newman DK. Bladder matters: urinary incontinence in nursing homes. Am J Nurs. Nov. 2004;104(11):57-9. Not eligible target population. [pmid: 15616452].
2501 Palmer MH, Newman DK. Bladder control educational needs of older adults. J Gerontol Nurs. Jan. 2006;32(1):28-32. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16475462].
2502 Palomba S, Russo T, Iuzzolino D, et al. Comparison between two laparoscopic retropubic urethropexy. Minerva Chir. Jun. 2002;57(3):323-9. Not eligible exposure. [pmid: 12029227].
2503 Panayi DC, Duckett J, Digesu GA, et al. Pre-operative opening detrusor pressure is predictive of detrusor overactivity following TVT in patients with pre-operative mixed urinary incontinence. Neurourology & Urodynamics. 2009;28(1):82-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 19089898].
2504 Pang MW, Chan LW, Yip SK. One-year urodynamic outcome and quality of life in patients with concomitant tension-free vaginal tape during pelvic floor reconstruction surgery for genitourinary prolapse and urodynamic stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2003;14(4):256-60. discussion 9–60. Not eligible exposure. [pmid: 14530838].
2505 Pang MW, Leung HY, Chan LW, et al. The impact of urinary incontinence on quality of life among women in Hong Kong. Hong Kong Med J. Jun. 2005;11(3):158-63. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15951580].
2506 Pang X, Boucher W, Triadafilopoulos G, et al. Mast cell and substance P-positive nerve involvement in a patient with both irritable bowel syndrome and interstitial cystitis. Urology. Mar. 1996;47(3):436-8. Not eligible target population. [pmid: 8633418].
2507 Pang X, Marchand J, Sant GR, et al. Increased number of substance P positive nerve fibres in interstitial cystitis. Br J Urol. Jun. 1995;75(6):744-50. Not eligible target population. [pmid: 7542136].
2508 Papanicolaou S, Hunskaar S, Lose G, et al. Assessment of bothersomeness and impact on quality of life of urinary incontinence in women in France, Germany, Spain and the UK. BJU Int. Oct. 2005;96(6):831-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16153212].
2509 Papanicolaou S, Pons ME, Hampel C, et al. Medical resource utilisation and cost of care for women seeking treatment for urinary incontinence in an outpatient setting. Examples from three countries participating in the PURE study. Maturitas. Nov. 30. 2005;52(Suppl 2):S35-47. not eligible outcomes. [pmid: 16297577].
2510 Paraiso MF, Barber MD, Muir TW, et al. Rectocele repair: a randomized trial of three surgical techniques including graft augmentation. Am J Obstet Gynecol. Dec. 2006;195(6):1762-71. Not eligible exposure. [pmid: 17132479].
2511 Parekh AR, Feng MI, Kirages D, et al. The role of pelvic floor exercises on post-prostatectomy incontinence. J Urol. Jul. 2003;170(1):130-3. Not eligible target population. [pmid: 12796664].
2512 Park R, Martin S, Goldberg JD, et al. Anastomotic strictures following radical prostatectomy: insights into incidence, effectiveness of intervention, effect on continence, and factors predisposing to occurrence. Urology. Apr. 2001;57(4):742-6. Not eligible target population. [pmid: 11306394].
2513 Park S, Hong B, Lee KS, et al. Risk factors of voiding dysfunction and patient satisfaction after tension-free vaginal tape procedure. J Korean Med Sci. Dec. 2005;20(6):1006-10. Not eligible exposure. [pmid: 16361813].
2514 Park SC, Jung SW, Lee JW, et al. The effects of tolterodine extended release and alfuzosin for the treatment of double-j stent-related symptoms. J Endourol. Nov. 2009;23(11):1913-7. Not eligible target population. [pmid: 19814699].
2515 Parkinson L, Chiarelli P, Byrne J, et al. Continence promotion for older hospital patients following surgery for fractured neck of femur: pilot of a randomized controlled trial. Clin Interv Aging. 2007;2(4):705-14. Not eligible target population. [pmid: 18225472].
2516 Parsons CL, Rosenberg MT, Sassani P, et al. Quantifying symptoms in men with interstitial cystitis/prostatitis, and its correlation with potassium-sensitivity testing. BJU international. 2005:86-90. Not eligible target population. [pmid: 15638901].
2517 Parsons JK, Marschke P, Maples P, et al. Effect of methylprednisolone on return of sexual function after nerve-sparing radical retropubic prostatectomy. Urology. Nov. 2004;64(5):987-90. Not eligible target population. [pmid: 15533491].
2518 Pascoe G. Transfix: a new range of all-silicone male incontinence sheaths. Br J Community Nurs. Jun. 2001;6(6):313-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11873207].
2519 Patel MD, McKevitt C, Lawrence E, et al. Clinical determinants of long-term quality of life after stroke. Age Ageing. May. 2007;36(3):316-22. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17374601].
2520 Paterson J, Dunn S, Kowanko I, et al. Selection of continence products: perspectives of people who have incontinence and their carers. Disabil Rehabil. Sep. 2. 2003;25(17):955-63. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12851083].
2521 Paterson J, Pinnock CB, Marshall VR. Pelvic floor exercises as a treatment for post-micturition dribble. Br J Urol. Jun. 1997;79(6):892-7. Not eligible target population. [pmid: 9202555].
2522 Patki P, Woodhouse JB, Patil K, et al. An effective day case treatment combination for refractory neuropathic mixed incontinence. Int Braz J Urol. Jan–Feb. 2008;34(1):63-71. discussion -2. Not eligible exposure. [pmid: 18341723].
2523 Patrick DL, Martin ML, Bushnell DM, et al. Cultural adaptation of a quality-of-life measure for urinary incontinence. Eur Urol. Nov. 1999;36(5):427-35. no associative hypothesis tested. [pmid: 10516455].
2524 Pauls RN, Occhino JA, Dryfhout V, et al. Effects of pregnancy on pelvic floor dysfunction and body image; a prospective study. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2008;19(11):1495-501. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18566731].
2525 Payne C, Allee T. Goal achievement provides new insights into interstitial cystitis/painful bladder syndrome symptoms and outcomes. Neurourol Urodyn. 2009;28(1):13-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 19089894].
2526 Payne CK. Biofeedback for community-dwelling individuals with urinary incontinence. Urology. 1998;51(2 SUPPL A):35-9. Review. [pmid: 9495734].
2527 Payne KA, Hendrix MR, Wade WJ. Caudal bupivacaine for postoperative analgesia in pediatric lower limb surgery. J Pediatr Surg. Feb. 1993;28(2):155-7. Not eligible target population. [pmid: 8437068].
2528 Peake S, Manderson L. The constraints of a normal life: the management of urinary incontinence by middle aged women. Women Health. 2003;37(3):37-51. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12839306].
2529 Peake S, Manderson L, Potts H. “Part and parcel of being a woman”: female urinary incontinence and constructions of control. Med Anthropol Q. Sep. 1999;13(3):267-85. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10509310].
2530 Pearman JW, Bailey M, Riley LP. Bladder instillations of trisdine compared with catheter introducer for reduction of bacteriuria during intermittent catheterisation of patients with acute spinal cord trauma. Br J Urol. May. 1991;67(5):483-90. Not eligible target population. [pmid: 1903999].
2531 Peeters ST, Lebesque JV, Heemsbergen WD, et al. Localized volume effects for late rectal and anal toxicity after radiotherapy for prostate cancer. Int J Radiat Oncol Biol Phys. Mar. 15. 2006;64(4):1151-61. Not eligible target population. [pmid: 16414208].
2532 Peifer DJ, Hanover RY. Clinical evaluation of the easy-flow catheter. J Rehabil Res Dev. Apr. 1997;34(2):215-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9108348].
2533 Peirce B. Wound care and the WOC nurse: how did we get here?. J Wound Ostomy Continence Nurs. Nov–Dec. 2007;34(6):602-4. Not eligible target population. [pmid: 18030097].
2534 Pemberton P, Brooks A, Eriksen CM, et al. A comparative study of two types of urinary sheath. Nurs Times. Feb. 14–20. 2006;102(7):36-41. Not eligible target population. [pmid: 16512048].
2535 Pena A. Anorectal malformations. Semin Pediatr Surg. Feb. 1995;4(1):35-47. Not eligible target population. [pmid: 7728507].
2536 Penalver MA, Barreau G, Sevin BU, et al. Surgery for the treatment of locally recurrent disease. J Natl Cancer Inst Monogr. 1996;(21):117-22. Not eligible target population. [pmid: 9023840].
2537 Penson DF, McLerran D, Feng Z, et al. 5-year urinary and sexual outcomes after radical prostatectomy: results from the prostate cancer outcomes study. J Urol. May. 2005;173(5):1701-5. Not eligible target population. [pmid: 15821561].
2538 Perez LM, Webster GD. Successful outcome of artificial urinary sphincters in men with post-prostatectomy urinary incontinence despite adverse implantation features. J Urol. Oct. 1992;148(4):1166-70. Not eligible target population. [pmid: 1404630].
2539 Perez MA, Meyerowitz BE, Lieskovsky G, et al. Quality of life and sexuality following radical prostatectomy in patients with prostate cancer who use or do not use erectile aids. Urology. Nov. 1997;50(5):740-6. Not eligible target population. [pmid: 9372885].
2540 Perez MA, Skinner EC, Meyerowitz BE. Sexuality and intimacy following radical prostatectomy: patient and partner perspectives. Health Psychol. May. 2002;21(3):288-93. Not eligible target population. [pmid: 12027035].
2541 Perissinotto MCR, Da’Ancona CAL, Campos RM, et al. Physiotherapeutic for Treatment of Post Radical Prostatectomy Urinary Incontinence. Paper presented at: 38th Annual Meeting of the International Continence Society (ICS 2008), Cairo International Congress Center (CICC). Cairo (Egypt). 20–24 Oct 2008. Not eligible target population.
2542 Perk H, Soyupek S, Serel TA, et al. Tension-free vaginal tape for surgical treatment of stress urinary incontinence: two years follow-up. Int J Urol. Mar. 2003;10(3):132-5. Not eligible exposure. [pmid: 12622708].
2543 Perrin L, Dauphinee SW, Corcos J, et al. Pelvic floor muscle training with biofeedback and bladder training in elderly women: a feasibility study. J Wound Ostomy Continence Nurs. May–Jun. 2005;32(3):186-99. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15931150].
2544 Perrotte P, Litwin MS, McGuire EJ, et al. Quality of life after salvage cryotherapy: the impact of treatment parameters. J Urol. Aug. 1999;162(2):398-402. Not eligible target population. [pmid: 10411046].
2545 Perry S, Shaw C, Assassa P, et al. An epidemiological study to establish the prevalence of urinary symptoms and felt need in the community: the Leicestershire MRC Incontinence Study. Leicestershire MRC Incontinence Study Team. J Public Health Med. Sep. 2000;22(3):427-34. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11077920].
2546 Persson J, Iosif C, Wolner-Hanssen P. Risk factors for rejection of synthetic suburethral slings for stress urinary incontinence: a case-control study. Obstet Gynecol. Apr. 2002;99(4):629-34. Not eligible exposure. [pmid: 12039125].
2547 Persson J, Teleman P, Eten-Bergquist C, et al. Cost-analyzes based on a prospective, randomized study comparing laparoscopic colposuspension with a tension-free vaginal tape procedure. Acta Obstet Gynecol Scand. Nov. 2002;81(11):1066-73. Not eligible exposure. [pmid: 12421176].
2548 Persson J, Wolner-Hanssen P. Laparoscopic Burch colposuspension for stress urinary incontinence: a randomized comparison of one or two sutures on each side of the urethra. Obstet Gynecol. Jan. 2000;95(1):151-5. Not eligible exposure. [pmid: 10636519].
2549 Peschers UM, Fanger G, Schaer GN, et al. Bladder neck mobility in continent nulliparous women. BJOG : an international journal of obstetrics and gynaecology. 2001:320-4. Not eligible target population. [pmid: 11281475].
2550 Peters K, Carrico D, Burks F. Validation of a sham for percutaneous tibial nerve stimulation (PTNS). Neurourol Urodyn. 2009;28(1):58-61. Not eligible target population. [pmid: 18671297].
2551 Peters KM, Killinger KA, Ibrahim IA, et al. The relationship between subjective and objective assessments of sacral neuromodulation effectiveness in patients with urgency-frequency. Neurourology & Urodynamics. 2008;27(8):775-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18551573].
2552 Peters TJ, Horrocks S, Stoddart H, et al. Factors associated with variations in older people’s use of community-based continence services. Health Soc Care Community. Jan. 2004;12(1):53-62. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14675365].
2553 Petersen T, Nielsen JB, Schroder HD. Intravesical capsaicin in patients with detrusor hyper-reflexia--a placebo-controlled cross-over study. Scand J Urol Nephrol. Apr. 1999;33(2):104-10. Not eligible target population. [pmid: 10360450].
2554 Petronijevic V, Lazovic M, Vlajkovic M, et al. Botulinum toxin type A in combination with standard urotherapy for children with dysfunctional voiding. J Urol. Dec. 2007;178(6):2599-602. discussion 602–3. Not eligible target population. [pmid: 17945299].
2555 Petros PE. New ambulatory surgical methods using an anatomical classification of urinary dysfunction improve stress, urge and abnormal emptying. Int Urogynecol J Pelvic Floor Dysfunct. 1997;8(5):270-7. Not eligible exposure. [pmid: 9557990].
2556 Petros PE, Richardson PA. Midurethral Tissue Fixation System sling -- a ‘micromethod’ for cure of stress incontinence -- preliminary report. Aust N Z J Obstet Gynaecol. Oct. 2005;45(5):372-5. Not eligible exposure. [pmid: 16171470].
2557 Petrou SP. Long-term durability of percutaneous tibial nerve stimulation for the treatment of overactive bladder. Int Braz J Urol. Jan–Feb. 2011;37(1):130-1. Editorial.
2558 Petrou SP, Jones J, Parra RO. Martius flap harvest site: patient self-perception. J Urol. May. 2002;167(5):2098-9. Not eligible exposure. [pmid: 11956448].
2559 Petrou SP, Lisson SW, Crook JE, et al. An exploration into patient preference for injectable therapy over surgery in the treatment of female urinary incontinence. Int Braz J Urol. Sep–Oct. 2006;32(5):578-82. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17081330].
2560 Petry H, Berry DL, Spichiger E, et al. Responses and experiences after radical prostatectomy: perceptions of married couples in Switzerland. Int J Nurs Stud. Jul. 2004;41(5):507-13. Not eligible target population. [pmid: 15120979].
2561 Pettersen R, Stien R, Wyller TB. Post-stroke urinary incontinence with impaired awareness of the need to void: clinical and urodynamic features. BJU Int. May. 2007;99(5):1073-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17437440].
2562 Pfister C, Cappele O, Dunet F, et al. Assessment of the intrinsic urethral sphincter component function in postprostatectomy urinary incontinence. Neurourol Urodyn. 2002;21(3):194-7. Not eligible target population. [pmid: 11948711].
2563 Pfister S. Bladder diaries and voiding patterns in older adults. J Gerontol Nurs. Mar. 1999;25(3):36-41. Comment. [pmid: 10362973].
2564 Pfister SM, Dougherty MC. Behavioral management for bladder control: response in selected rural residential care homes. J Community Health Nurs. 1994;11(3):155-64. Not eligible target population. [pmid: 7964934].
2565 Pfisterer MH, Johnson TM 2nd, Jenetzky E, et al. Geriatric patients’ preferences for treatment of urinary incontinence: a study of hospitalized, cognitively competent adults aged 80 and older. J Am Geriatr Soc. Dec. 2007;55(12):2016-22. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17979956].
2566 Pham K, Guralnick ML, O’Connor RC. Unilateral versus bilateral stage I neuromodulator lead placement for the treatment of refractory voiding dysfunction. Neurourology & Urodynamics. 2008;27(8):779-81. 21042. Not eligible exposure. [pmid: 18551562].
2567 Pham T, Kenton K, Mueller E, et al. New pelvic symptoms are common after reconstructive pelvic surgery. Am J Obstet Gynecol. Jan. 2009;200(1):88 e1-5. Not eligible exposure. [pmid: 18845285].
2568 Phelan MW, Franks M, Somogyi GT, et al. Botulinum toxin urethral sphincter injection to restore bladder emptying in men and women with voiding dysfunction. J Urol. Apr. 2001;165(4):1107-10. Not eligible target population. [pmid: 11257648].
2569 Phelan S, Kanaya AM, Subak LL, et al. Prevalence and risk factors for urinary incontinence in overweight and obese diabetic women: action for health in diabetes (look ahead) study. Diabetes Care. Aug. 2009;32(8):1391-7. Not eligible target population. [pmid: 19487639].
2570 Philip J, Willmott S, Irwin P. Interstitial cystitis versus detrusor overactivity: a comparative, randomized, controlled study of cystometry using saline and 0.3 M potassium chloride. J Urol. Feb. 2006;175(2):566-70. discussion 70–1. Not eligible exposure. [pmid: 16406997].
2571 Phillips CD, Morris JN, Hawes C, et al. Association of the Resident Assessment Instrument (RAI) with changes in function, cognition, and psychosocial status. J Am Geriatr Soc. Aug. 1997;45(8):986-93. Not eligible target population. [pmid: 9256853].
2572 Pianezza ML, Joffe R, Chugh T, et al. Long-term patient satisfaction following cadaveric pubovaginal sling incontinence surgery using the UDI and IIQ-7 questionnaires. Neurourol Urodyn. 2007;26(2):185-9. Not eligible exposure. [pmid: 16998860].
2573 Piault E, Evans CJ, Espindle D, et al. Development and validation of the Overactive Bladder Satisfaction (OAB-S) Questionnaire. Neurourol Urodyn. 2008;27(3):179-90. Not eligible outcomes. [pmid: 17565727].
2574 Pickersgill F. Winning confidence. Nurs Stand. Apr. 2–8. 2008;22(30):20-1. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18459607].
2575 Pinar K, Moore KN, Smits E, et al. Leg bag comparison: reported skin health, comfort, and satisfaction. J Wound Ostomy Continence Nurs. May–Jun. 2009;36(3):319-26. Not eligible target population. [pmid: 19448514].
2576 Pinggera GM, Feuchtner G, Frauscher F, et al. Effects of local estrogen therapy on recurrent urinary tract infections in young females under oral contraceptives. Eur Urol. Feb. 2005;47(2):243-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15661421].
2577 Pinkawa M, Fischedick K, Asadpour B, et al. Health-related quality of life after adjuvant and salvage postoperative radiotherapy for prostate cancer - a prospective analysis. Radiother Oncol. Jul. 2008;88(1):135-9. Not eligible target population. [pmid: 18022263].
2578 Pinto AC, Baracat F, Montellato ND, et al. The short-term effect of surgical treatment for stress urinary incontinence using sub urethral support techniques on sexual function. Int Braz J Urol. Nov–Dec. 2007;33(6):822-8. Not eligible exposure. [pmid: 18199351].
2579 Pisarska M, Sajdak S. Lower urinary tract function after postoperative radiotherapy in the treatment of cervical cancer. Eur J Gynaecol Oncol. 2003;24(6):490-4. Not eligible target population. [pmid: 14658587].
2580 Pisters LL, Dinney CP, Pettaway CA, et al. A feasibility study of cryotherapy followed by radical prostatectomy for locally advanced prostate cancer. J Urol. Feb. 1999;161(2):509-14. Not eligible target population. [pmid: 9915437].
2581 Pisters LL, von Eschenbach AC, Scott SM, et al. The efficacy and complications of salvage cryotherapy of the prostate. J Urol. Mar. 1997;157(3):921-5. Not eligible target population. [pmid: 9072600].
2582 Pohar SL, Jones CA, Warren S, et al. Health status and health care utilization of multiple sclerosis in Canada. Can J Neurol Sci. May. 2007;34(2):167-74. Not eligible target population. [pmid: 17598593].
2583 Pollack J, Holm T, Cedermark B, et al. Late adverse effects of short-course preoperative radiotherapy in rectal cancer. Br J Surg. Dec. 2006;93(12):1519-25. Not eligible target population. [pmid: 17054311].
2584 Ponholzer A, Brossner C, Struhal G, et al. Lower urinary tract symptoms, urinary incontinence, sexual function and quality of life after radical prostatectomy and external beam radiation therapy: real life experience in Austria. World J Urol. Aug. 2006;24(3):325-30. Not eligible target population. [pmid: 16688458].
2585 Poon CI, Zimmern PE. Is there a role for periurethral collagen injection in the management of urodynamically proven mixed urinary incontinence?. Urology. Apr. 2006;67(4):725-9. discussion 9–30. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16618559].
2586 Popat R, Apostolidis A, Kalsi V, et al. A comparison between the response of patients with idiopathic detrusor overactivity and neurogenic detrusor overactivity to the first intradetrusor injection of botulinum-A toxin. J Urol. Sep. 2005;174(3):984-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16094019].
2587 Porena M, Costantini E, Frea B, et al. Tension-free vaginal tape versus transobturator tape as surgery for stress urinary incontinence: results of a multicentre randomised trial. Eur Urol. Nov. 2007;52(5):1481-90. Not eligible exposure. [pmid: 17482343].
2588 Porpiglia F, Fiori C, Grande S, et al. Selective versus standard ligature of the deep venous complex during laparoscopic radical prostatectomy: effects on continence, blood loss, and margin status. Eur Urol. Jun. 2009;55(6):1377-83. Not eligible target population. [pmid: 19243886].
2589 Porru D, Campus G, Caria A, et al. Impact of early pelvic floor rehabilitation after transurethral resection of the prostate. Neurourol Urodyn. 2001;20(1):53-9. Not eligible target population. [pmid: 11135382].
2590 Porru D, Tinelli C, Gerardini M, et al. Evaluation of urinary and general symptoms and correlation with other clinical parameters in interstitial cystitis patients. Neurourol Urodyn. 2005;24(1):69-73. Not eligible target population. [pmid: 15573384].
2591 Potosky AL, Davis WW, Hoffman RM, et al. Five-year outcomes after prostatectomy or radiotherapy for prostate cancer: the prostate cancer outcomes study. J Natl Cancer Inst. Sep. 15. 2004;96(18):1358-67. Not eligible target population. [pmid: 15367568].
2592 Potosky AL, Legler J, Albertsen PC, et al. Health outcomes after prostatectomy or radiotherapy for prostate cancer: results from the Prostate Cancer Outcomes Study. J Natl Cancer Inst. Oct. 4. 2000;92(19):1582-92. Not eligible target population. [pmid: 11018094].
2593 Potter DM, Griffiths DJ. Omnibus permutation tests of the overall null hypothesis in datasets with many covariates. J Biopharm Stat. May. 2006;16(3):327-41. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16724488].
2594 Pottle B. Continence. Reformed role. Nurs Times. Sep 29-Oct 5. 1993;89(39):63-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8415104].
2595 Powel LL, Clark JA. The value of the marginalia as an adjunct to structured questionnaires: experiences of men after prostate cancer surgery. Qual Life Res. Apr. 2005;14(3):827-35. Not eligible target population. [pmid: 16022075].
2596 Pozowski J, Sobanski A, Dudkiewicz D, et al. Quality of life in women with urinary stress incontinence and evaluation of tension-free vaginal tape treatment. Gynecol Obstet Invest. 2007;64(1):55-60. Not eligible exposure. [pmid: 17287606].
2597 Prasad RS, Smith SJ, Wright H. Lower abdominal pressure versus external bladder stimulation to aid bladder emptying in multiple sclerosis: a randomized controlled study. Clin Rehabil. Feb. 2003;17(1):42-7. Not eligible target populaion. [pmid: 12617378].
2598 Prashar S, Simons A, Bryant C, et al. Attitudes to vaginal/urethral touching and device placement in women with urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 2000;11(1):4-8. Not eligible exposure. [pmid: 10738927].
2599 Prasher VP, Filer A. Behavioural disturbance in people with Down’s syndrome and dementia. J Intellect Disabil Res. Oct. 1995;39(Pt 5):432-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8555719].
2600 Praud C, Sebe P, Bierinx AS, et al. Improvement of urethral sphincter deficiency in female rats following autologous skeletal muscle myoblasts grafting. Cell Transplant. 2007;16(7):741-9. Not eligible target population. [pmid: 18019363].
2601 Pregazzi R, Sartore A, Bortoli P, et al. Perineal ultrasound evaluation of urethral angle and bladder neck mobility in women with stress urinary incontinence. BJOG. Jul. 2002;109(7):821-7. Not eligible exposure. [pmid: 12135220].
2602 Primus G. One year follow-up on the SPARC sling system for the treatment of female urodynamic stress incontinence. Int J Urol. Nov. 2006;13(11):1410-4. Not eligible exposure. [pmid: 17083393].
2603 Primus G, Pummer K. Oxybutynin hydrochloride in the management of detrusor instability. Int Urol Nephrol. 1990;22(3):243-8. Not eligible case series. [pmid: 2210980].
2604 Protogerou V, Moschou M, Antoniou N, et al. Modified S-pouch neobladder vs ileal conduit and a matched control population: a quality-of-life survey. BJU Int. Aug. 2004;94(3):350-4. Not eligible target population. [pmid: 15291866].
2605 Prutz C, Snedecor S, Botteman M, et al. Fesoterodine for the treatment of overactive bladder - a cost -effectiveness case study of Sweden. Paper presented at: International Society for Pharmacoeconomics & Outcomes Research Annual International Congress. May 3–7, 2008. 2008. Toronto, Ontario, Canada. Not eligible outcomes.
2606 Pulvino JQ, Flynn MK, Buchsbaum GM. Urinary incontinence secondary to severe labial agglutination. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2008;19(2):253-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17594045].
2607 Puri A, Bhatnagar V, Grover VP, et al. Urodynamics-based evidence for the beneficial effect of imipramine on valve bladders in children. Eur J Pediatr Surg. Oct. 2005;15(5):347-53. Not eligible target population. [pmid: 16254848].
2608 Quadri G, Magatti F, Belloni C, et al. Marshall-Marchetti-Krantz urethropexy and Burch colposuspension for stress urinary incontinence in women with low pressure and hypermobility of the urethra: early results of a prospective randomized clinical trial. Am J Obstet Gynecol. Jul. 1999;181(1):12-8. Not eligible exposure. [pmid: 10411835].
2609 Quallich SA, Ohl DA. Artificial urinary sphincter, Part II: Patient teaching and perioperative care. Urol Nurs. Aug. 2003;23(4):269-73. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14552072].
2610 Quek ML, Ginsberg DA. Long-term urodynamics followup of bladder augmentation for neurogenic bladder. J Urol. Jan. 2003;169(1):195-8. Not eligible exposure. [pmid: 12478134].
2611 Quinn P, Goka J, Richardson H. Assessment of an electronic daily diary in patients with overactive bladder. BJU Int. May. 2003;91(7):647-52. Not eligible outcomes. [pmid: 12699477].
2612 Qureshi A, Nicolaou J, Lynch CB, et al. Outcome of tension-free vaginal tape (TVT) procedure in women with stress urinary incontinence--patients’ perspective. J Obstet Gynaecol. May. 2003;23(3):297-300. Not eligible exposure. [pmid: 12850866].
2613 Rabin JM. Clinical use of the FemAssist device in female urinary incontinence. J Med Syst. Aug. 1998;22(4):257-71. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9690182].
2614 Rabin JM, McNett J, Badlani GH. Computerized voiding diary. Neurourol Urodyn. 1993;12(6):541-53. discussion 53–4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8312939].
2615 Rabin JM, McNett J, Badlani GH. “Compu-Void II”: the computerized voiding diary. J Med Syst. Feb. 1996;20(1):19-34. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8708489].
2616 Rackley R, Weiss JP, Rovner ES, et al. Nighttime dosing with tolterodine reduces overactive bladder-related nocturnal micturitions in patients with overactive bladder and nocturia. Urology. Apr. 2006;67(4):731-6. discussion 6. Not eligible exposure. [pmid: 16618562].
2617 Radley SC, Chapple CR, Bryan NP, et al. Effect of methoxamine on maximum urethral pressure in women with genuine stress incontinence: a placebo-controlled, double-blind crossover study. Neurourol Urodyn. 2001;20(1):43-52. Not eligible exposure. [pmid: 11135381].
2618 Radley SC, Rosario DJ, Chapple CR, et al. Conventional and ambulatory urodynamic findings in women with symptoms suggestive of bladder overactivity. J Urol. Dec. 2001;166(6):2253-8. Not eligible outcomes. [pmid: 11696746].
2619 Radojicic ZI, Perovic SV, Milic NM. Is it reasonable to treat refractory voiding dysfunction in children with botulinum-A toxin?. J Urol. Jul. 2006;176(1):332-6. discussion 6. Not eligible target population. [pmid: 16753436].
2620 Radziszewski P, Borkowski A, Torz C, et al. Distribution of collagen type VII in connective tissues of postmenopausal stress-incontinent women. Gynecol Endocrinol. Mar. 2005;20(3):121-6. not eligible outcomes. [pmid: 16019349].
2621 Ragins AI, Shan J, Thom DH, et al. Effects of urinary incontinence, comorbidity and race on quality of life outcomes in women. J Urol. Feb. 2008;179(2):651-5. discussion 5. Not eligible exposure. [pmid: 18082212].
2622 Rahman S, Griffin HJ, Quinn NP, et al. Quality of life in Parkinson’s disease: the relative importance of the symptoms. Mov Disord. Jul. 30. 2008;23(10):1428-34. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18543333].
2623 Rait G, Fletcher A, Smeeth L, et al. Prevalence of cognitive impairment: results from the MRC trial of assessment and management of older people in the community. Age Ageing. May. 2005;34(3):242-8. no associative hypothesis tested. [pmid: 15863409].
2624 Rajpurkar AD, Onur R, Singla A. Patient satisfaction and clinical efficacy of the new perineal bone-anchored male sling. Eur Urol. Feb. 2005;47(2):237-42. discussion 42. Not eligible target population. [pmid: 15661420].
2625 Ramoso-Jalbuena J. Climacteric Filipino women: a preliminary survey in the Philippines. Maturitas. Oct. 1994;19(3):183-90. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7799824].
2626 Ramsay AK, Granitsiotis P, Conn IG. The use of the artificial urinary sphincter in the West of Scotland: a single centre 10-year experience. Scott Med J. May. 2007;52(2):14-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17536635].
2627 Rannestad T, Eikeland OJ, Helland H, et al. Are the physiologically and psychosocially based symptoms in women suffering from gynecological disorders alleviated by means of hysterectomy?. J Womens Health Gend Based Med. Jul–Aug. 2001;10(6):579-87. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11559455].
2628 Rantz MJ. Examining MDS (Minimum Data Set) resident assessments for the impact on public policy. J Long Term Care Adm. Fall-Winter. 1995;23(3):18-21. Not eligible target population. [pmid: 10156663].
2629 Rao J, Koay SK, Lau WK, et al. Patient-reported urinary continence (third-party interview): results of post-radical retropubic prostatectomy in Singaporeans. Asian J Surg. Jul. 2005;28(3):207-10. Not eligible target population. [pmid: 16024318].
2630 Rapp DE, Kobashi KC. Outcomes following sling surgery: importance of definition of success. J Urol. Sep. 2008;180(3):998-1002. Not eligible exposure. [pmid: 18639263].
2631 Rapp DE, Nazemi TM, Kobashi KC, et al. Transvaginal bone-anchored sling for the treatment of female stress urinary incontinence: effect of Valsalva leak point pressure and prior pelvic surgery on outcomes. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2008;19(9):1211-5. Not eligible exposure. [pmid: 18465078].
2632 Rapp DE, Reynolds WS, Lucioni A, et al. Advance Sling Placement in the Treatment of Post-Prostatectomy Urinary Incontinence. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Not eligible target population.
2633 Rapp K, Lamb SE, Buchele G, et al. Prevention of falls in nursing homes: subgroup analyses of a randomized fall prevention trial. Journal of the American Geriatrics Society. 2008:1092-7. Not eligible target population. [pmid: 18482303].
2634 Rasmussen A, Mouritsen L, Dalgaard A, et al. Twenty-four hour pad weighing test: reproducibility and dependency of activity level and fluid intake. Neurourol Urodyn. 1994;13(3):261-5. Not eligible outcomes. [pmid: 7920683].
2635 Ratto C, Grillo E, Parello A, et al. Sacral neuromodulation in treatment of fecal incontinence following anterior resection and chemoradiation for rectal cancer. Dis Colon Rectum. May. 2005;48(5):1027-36. Not eligible target population. [pmid: 15785890].
2636 Raz S, Nitti VW, Bregg KJ. Transvaginal repair of enterocele. J Urol. Apr. 1993;149(4):724-30. Not eligible exposure. [pmid: 8455231].
2637 Rechberger T, Donica H, Baranowski W, et al. Female urinary stress incontinence in terms of connective tissue biochemistry. Eur J Obstet Gynecol Reprod Biol. May. 1993;49(3):187-91. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8405633].
2638 Rechberger T, Futyma K, Jankiewicz K, et al. Body mass index does not influence the outcome of anti-incontinence surgery among women whereas menopausal status and ageing do: a randomised trial. Int Urogynecol J Pelvic Floor Dysfunct. Jul. 2010;21(7):801-6. Not eligible exposure. [pmid: 20179903].
2639 Rechberger T, Futyma K, Miotla P, et al. Changing trends in the surgical treatment of female stress urinary incontinence--twenty two years observation. Ginekol Pol. Jan. 2008;79(1):36-41. Not eligible exposure. [pmid: 18510048].
2640 Rechberger T, Rzezniczuk K, Skorupski P, et al. A randomized comparison between monofilament and multifilament tapes for stress incontinence surgery. Int Urogynecol J Pelvic Floor Dysfunct. Dec. 2003;14(6):432-6. Not eligible exposure. [pmid: 14677007].
2641 Reddy SM, Ruby J, Wallace M, et al. Patient self-assessment of complications and quality of life after conformal neutron and photon irradiation for localized prostate cancer. Radiat Oncol Investig. 1997;5(5):252-6. Not eligible target population. [pmid: 9372548].
2642 Reeve BB, Potosky AL, Willis GB. Should function and bother be measured and reported separately for prostate cancer quality-of-life domains?. Urology. Sep. 2006;68(3):599-603. Not eligible target population. [pmid: 16979720].
2643 Rehder P, Gozzi C. Transobturator sling suspension for male urinary incontinence including post-radical prostatectomy. Eur Urol. Sep. 2007;52(3):860-6. Not eligible target population. [pmid: 17316969].
2644 Rehder P, Lunacek A, Bartsch G, et al. Principles of Anatomy and Histology for Male Transobturator Tape (TOT) Suspension for the Treatment of Post-Prostatectomy Urinary Incontinence. Paper presented at: 21st Annual Congress of the European Association of Urology (EAU 2006), Palais des Congres. Paris (France). 5–8 Apr 2006. Not eligible target population.
2645 Rehman J, Ragab MM, Venkatesh R, et al. Laparoscopic radical prostatectomy: Washington University initial experience and prospective evaluation of quality of life. J Endourol. Apr. 2004;18(3):277-87. Not eligible target population. [pmid: 15225395].
2646 Reichelt O, Weirich T, Wunderlich H, et al. Pubovaginal cutaneous fascial sling procedure for stress urinary incontinence: 10 years’ experience. Urol Int. 2004;72(4):318-23. discussion 23–4. Not eligible exposure. [pmid: 15153730].
2647 Reid IR, Eastell R, Fogelman I, et al. A comparison of the effects of raloxifene and conjugated equine estrogen on bone and lipids in healthy postmenopausal women. Arch Intern Med. Apr. 26. 2004;164(8):871-9. Not eligible target population. [pmid: 15111373].
2648 Reinberg Y, Crocker J, Wolpert J, et al. Therapeutic efficacy of extended release oxybutynin chloride, and immediate release and long acting tolterodine tartrate in children with diurnal urinary incontinence. J Urol. Jan. 2003;169(1):317-9. Not eligible target population. [pmid: 12478180].
2649 Reis F, Netto NR Jr, Reinato JA, et al. The impact of prostatectomy and brachytherapy in patients with localized prostate cancer. Int Urol Nephrol. 2004;36(2):187-90. Not eligible target population. [pmid: 15368690].
2650 Reitz A, Schmid DM, Curt A, et al. Afferent fibers of the pudendal nerve modulate sympathetic neurons controlling the bladder neck. Neurourol Urodyn. 2003;22(6):597-601. Not eligible population. [pmid: 12951671].
2651 Reitz AB, Gupta SK, Huang Y, et al. The preparation and human muscarinic receptor profiling of oxybutynin and N-desethyloxybutynin enantiomers. Med Chem. Nov. 2007;3(6):543-5. Review. [pmid: 18045203].
2652 Remsburg RE, Palmer MH, Langford AM, et al. Staff compliance with and ratings of effectiveness of a prompted voiding program in a long-term care facility. J Wound Ostomy Continence Nurs. Sep. 1999;26(5):261-9. Not eligible target population. [pmid: 10795210].
2653 Resnick B, Keilman LJ, Calabrese B, et al. Nursing staff beliefs and expectations about continence care in nursing homes. J Wound Ostomy Continence Nurs. Nov–Dec. 2006;33(6):610-8. Not eligible target population. [pmid: 17108770].
2654 Resnick NM, Ouslander JG. Urinary incontinence--where do we stand and where do we go from here?. J Am Geriatr Soc. Mar. 1990;38(3):263-4. Comment. [pmid: 2313009].
2655 Rett MT, Simoes JA, Herrmann V, et al. Management of stress urinary incontinence with surface electromyography-assisted biofeedback in women of reproductive age. Phys Ther. Feb. 2007;87(2):136-42. Level of evidence. [pmid: 17213411].
2656 Reuben DB, Frank JC, Hirsch SH, et al. A randomized clinical trial of outpatient comprehensive geriatric assessment coupled with an intervention to increase adherence to recommendations. J Am Geriatr Soc. Mar. 1999;47(3):269-76. not eligible outcomes. [pmid: 10078887].
2657 Reuben DB, Maly RC, Hirsch SH, et al. Physician implementation of and patient adherence to recommendations from comprehensive geriatric assessment. Am J Med. Apr. 1996;100(4):444-51. Not eligible target population. [pmid: 8610732].
2658 Reuben DB, Roth C, Kamberg C, et al. Restructuring primary care practices to manage geriatric syndromes: the ACOVE-2 intervention. J Am Geriatr Soc. Dec. 2003;51(12):1787-93. not eligible outcomes. [pmid: 14687359].
2659 Reymert J, Hunskaar S. Why do only a minority of perimenopausal women with urinary incontinence consult a doctor?. Scand J Prim Health Care. Sep. 1994;12(3):180-3. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7997696].
2660 Reynolds WS, Patel R, Msezane L, et al. Current use of artificial urinary sphincters in the United States. J Urol. Aug. 2007;178(2):578-83. Not eligible target population. [pmid: 17570407].
2661 Rezapour M, Falconer C, Ulmsten U. Tension-Free vaginal tape (TVT) in stress incontinent women with intrinsic sphincter deficiency (ISD)--a long-term follow-up. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(Suppl 2):S12-4. Not eligible exposure. [pmid: 11450973].
2662 Rezapour M, Ulmsten U. Tension-Free vaginal tape (TVT) in women with mixed urinary incontinence--a long-term follow-up. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(Suppl 2):S15-8. Not eligible exposure. [pmid: 11450974].
2663 Rezapour M, Ulmsten U. Tension-Free vaginal tape (TVT) in women with recurrent stress urinary incontinence--a long-term follow up. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(Suppl 2):S9-11. Not eligible exposure. [pmid: 11450980].
2664 Rhodes P, Parker G. The role of the continence adviser in England and Wales. Int J Nurs Stud. Oct. 1995;32(5):423-33. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8550303].
2665 Ricci JA, Baggish JS, Hunt TL, et al. Coping strategies and health care-seeking behavior in a US national sample of adults with symptoms suggestive of overactive bladder. Clin Ther. Aug. 2001;23(8):1245-59. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11558861].
2666 Richardson DA. Conservative management of urinary incontinence. A symposium. J Reprod Med. Sep. 1993;38(9):659-61. Symposium materials. [pmid: 8254583].
2667 Richardson DA, Miller KL, Siegel SW, et al. Pelvic floor electrical stimulation: a comparison of daily and every-other-day therapy for genuine stress incontinence. Urology. Jul. 1996;48(1):110-8. Level of evidence. [pmid: 8693630].
2668 Richter HE, Albo ME, Zyczynski HM, et al. Retropubic versus transobturator midurethral slings for stress incontinence. N Engl J Med. Jun. 3. 2010;362(22):2066-76. Not eligible exposure. [pmid: 20479459].
2669 Richter HE, Burgio KL, Brubaker L, et al. Factors associated with incontinence frequency in a surgical cohort of stress incontinent women. Am J Obstet Gynecol. Dec. 2005;193(6):2088-93. Not eligible exposure. [pmid: 16325621].
2670 Richter HE, Burgio KL, Goode PS, et al. Non-surgical management of stress urinary incontinence: ambulatory treatments for leakage associated with stress (ATLAS) trial. Clin Trials. 2007;4(1):92-101. No primary results. [pmid: 17327249].
2671 Richter HE, Burgio KL, Holley RL, et al. Cadaveric fascia lata sling for stress urinary incontinence: a prospective quality-of-life analysis. Am J Obstet Gynecol. Dec. 2003;189(6):1590-5. discussion 5–6. Not eligible exposure. [pmid: 14710075].
2672 Richter HE, Creasman JM, Myers DL, et al. Urodynamic characterization of obese women with urinary incontinence undergoing a weight loss program: the Program to Reduce Incontinence by Diet and Exercise (PRIDE) trial. Int Urogynecol J Pelvic Floor Dysfunct. Dec. 2008;19(12):1653-8. Not eligible exposure. [pmid: 18679560].
2673 Richter HE, Diokno A, Kenton K, et al. Predictors of treatment failure 24 months after surgery for stress urinary incontinence. J Urol. Mar. 2008;179(3):1024-30. Not eligible exposure. [pmid: 18206917].
2674 Richter HE, Goode PS, Brubaker L, et al. Two-year outcomes after surgery for stress urinary incontinence in older compared with younger women. Obstetrics & Gynecology. Sep. 2008;112(3):621-9. Not eligible exposure. [pmid: 18757661].
2675 Richter HE, Norman AM, Burgio KL, et al. Tension-free vaginal tape: a prospective subjective and objective outcome analysis. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2005;16(2):109-13. Not eligible exposure. [pmid: 15789144].
2676 Richter HE, Nygaard I, Burgio KL, et al. Lower urinary tract symptoms, quality of life and pelvic organ prolapse: irritative bladder and obstructive voiding symptoms in women planning to undergo abdominal sacrocolpopexy for advanced pelvic organ prolapse. J Urol. Sep. 2007;178(3 Pt 1):965-9. discussion 9. Not eligible exposure. [pmid: 17632167].
2677 Richter HE, Varner RE, Sanders E, et al. Effects of pubovaginal sling procedure on patients with urethral hypermobility and intrinsic sphincteric deficiency: would they do it again?. Am J Obstet Gynecol. Jan. 2001;184(2):14-9. Not eligible exposure. [pmid: 11174473].
2678 Ricketts RR, Woodard JR, Zwiren GT, et al. Modern treatment of cloacal exstrophy. J Pediatr Surg. Apr. 1991;26(4):444-8. discussion 8–50. Not eligible target population. [pmid: 2056406].
2679 Rigby D. Promoting continence with electrostimulation. Prof Nurse. Apr. 1996;11(7):431-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8700927].
2680 Rigby D. The value of continence training: does it change clinical practice?. Br J Nurs. Apr 24-May 7. 2003;12(8):484-6. 8. 92. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12743478].
2681 Rigby M. Lost continence. Nurs Stand. Sep 29-Oct 5. 1999;14(2):14-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10786572].
2682 Rinne K, Laurikainen E, Kivela A, et al. A randomized trial comparing TVT with TVT-O: 12-month results. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2008;19(8):1049-54. Not eligible exposure. [pmid: 18373046].
2683 Rintala R, Lahdenne P, Lindahl H, et al. Anorectal function in adults operated for a benign sacrococcygeal teratoma. J Pediatr Surg. Sep. 1993;28(9):1165-7. Not eligible target population. [pmid: 8308684].
2684 Rintala R, Mildh L, Lindahl H. Fecal continence and quality of life for adult patients with an operated high or intermediate anorectal malformation. J Pediatr Surg. Jun. 1994;29(6):777-80. Not eligible target population. [pmid: 8078019].
2685 Ripetti V, Caputo D, Ausania F, et al. Sacral nerve neuromodulation improves physical, psychological and social quality of life in patients with fecal incontinence. Tech Coloproctol. Dec. 2002;6(3):147-52. Not eligible exposure. [pmid: 12525907].
2686 Rivera R, Gousse A. Does postmenopausal hormone therapy cause urinary incontinence?. Nat Clin Pract Urol. Jun. 2006;3(6):304-5. Not eligible exposure. [pmid: 16763639].
2687 Rizk DE, Raaschou T, Mason N, et al. Evidence of progesterone receptors in the mucosa of the urinary bladder. Scand J Urol Nephrol. Sep. 2001;35(4):305-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11676357].
2688 Rizk DE, Shaheen H, Thomas L, et al. The prevalence and determinants of health care-seeking behavior for urinary incontinence in United Arab Emirates women. Int Urogynecol J Pelvic Floor Dysfunct. 1999;10(3):160-5. Not eligible target population. [pmid: 10430008].
2689 Robert M, Farrell SA, Easton WA, et al. Choice of surgery for stress incontinence. J Obstet Gynaecol Can. Oct. 2005;27(10):964-80. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16411012].
2690 Roberts JM, Gonzalez CB, Sampselle C. Why do supportive birth attendants become directive of maternal bearing-down efforts in second-stage labor?. J Midwifery Womens Health. Mar–Apr. 2007;52(2):134-41. Not eligible target population. [pmid: 17336819].
2691 Roberts RG, Garely AD, Bavendam T. Safety and tolerability of tolterodine for the treatment of overactive bladder in adults. Am J Manag Care. Jul. 2005;11(4 Suppl):S158-62. Review. [pmid: 16161389].
2692 Roberts RO, Jacobsen SJ, Rhodes T, et al. Urinary incontinence in a community-based cohort: prevalence and healthcare-seeking. J Am Geriatr Soc. Apr. 1998;46(4):467-72. Not eligible target population. [pmid: 9560070].
2693 Robinson BE, Barry PP, Renick N, et al. Physician confidence and interest in learning more about common geriatric topics: a needs assessment. J Am Geriatr Soc. Jul. 2001;49(7):963-7. no associative hypothesis tested. [pmid: 11527489].
2694 Robinson D, Anders K, Cardozo L, et al. Can ultrasound replace ambulatory urodynamics when investigating women with irritative urinary symptoms?. BJOG. Feb. 2002;109(2):145-8. Not eligible outcomes. [pmid: 11888096].
2695 Robinson D, Cardozo L, Akeson M, et al. Antidiuresis: a new concept in managing female daytime urinary incontinence. BJU Int. May. 2004;93(7):996-1000. Not eligible exposure. [pmid: 15142150].
2696 Robinson D, Pearce KF, Preisser JS, et al. Relationship between patient reports of urinary incontinence symptoms and quality of life measures. Obstet Gynecol. Feb. 1998;91(2):224-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9469280].
2697 Robinson JP. Managing urinary incontinence in the nursing home: residents’ perspectives. J Adv Nurs. Jan. 2000;31(1):68-77. Not eligible target population. [pmid: 10632795].
2698 Robinson JP. Phases of the qualitative research interview with institutionalized elderly individuals. J Gerontol Nurs. Nov. 2000;26(11):17-23. Not eligible target population. [pmid: 11883617].
2699 Robinson JP, Avi-Itzhak T, McCorkle R. Psychometric properties of the Male Urogenital Distress Inventory (MUDI) and Male Urinary Symptom Impact Questionnaire (MUSIQ) in patients following radical prostatectomy. Urol Nurs. Dec. 2007;27(6):512-8. Not eligible target population. [pmid: 18217534].
2700 Robinson JP, Shea JA. Development and testing of a measure of health-related quality of life for men with urinary incontinence. J Am Geriatr Soc. May. 2002;50(5):935-45. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12028184].
2701 Robinson JW, Donnelly BJ, Coupland K, et al. Quality of life 2 years after salvage cryosurgery for the treatment of local recurrence of prostate cancer after radiotherapy. Urol Oncol. Nov–Dec. 2006;24(6):472-86. Not eligible target population. [pmid: 17138127].
2702 Roderick T, Paul M, Christopher M, et al. Urethral retro-resistance pressure: association with established measures of incontinence severity and change after midurethral tape insertion. Neurourology & Urodynamics. 2009;28(1):86-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18671296].
2703 Rodhe N, Molstad S, Englund L, et al. Asymptomatic bacteriuria in a population of elderly residents living in a community setting: prevalence, characteristics and associated factors. Fam Pract. Jun. 2006;23(3):303-7. no associated hypothesis tested. [pmid: 16595541].
2704 Rodriguez LV, Berman J, Raz S. Polypropylene sling for treatment of stress urinary incontinence: an alternative to tension-free vaginal tape. Tech Urol. Jun. 2001;7(2):87-9. Not eligible exposure. [pmid: 11383999].
2705 Rodriguez LV, Blander DS, Dorey F, et al. Discrepancy in patient and physician perception of patient’s quality of life related to urinary symptoms. Urology. Jul. 2003;62(1):49-53. Not eligible exposure. [pmid: 12837421].
2706 Rodriguez LV, Bukkapatnam R, Shah SM, et al. Transvaginal paravaginal repair of high-grade cystocele central and lateral defects with concomitant suburethral sling: report of early results, outcomes, and patient satisfaction with a new technique. Urology. Nov. 2005;66(5 Suppl):57-65. Not eligible exposure. [pmid: 16194709].
2707 Rodriguez LV, de Almeida F, Dorey F, et al. Does Valsalva leak point pressure predict outcome after the distal urethral polypropylene sling? Role of urodynamics in the sling era. J Urol. Jul. 2004;172(1):210-4. Not eligible exposure. [pmid: 15201776].
2708 Rodriguez LV, Raz S. Prospective analysis of patients treated with a distal urethral polypropylene sling for symptoms of stress urinary incontinence: surgical outcome and satisfaction determined by patient driven questionnaires. J Urol. Sep. 2003;170(3):857-63. discussion 63. Not eligible exposure. [pmid: 12913716].
2709 Rodriguez NA, Sackley CM, Badger FJ. Exploring the facets of continence care: a continence survey of care homes for older people in Birmingham. J Clin Nurs. May. 2007;16(5):954-62. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17462046].
2710 Roe B, Doll H. Prevalence of urinary incontinence and its relationship with health status. J Clin Nurs. Mar. 2000;9(2):178-87. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11111607].
2711 Roe B, Doll H, Wilson K. Help seeking behaviour and health and social services utilisation by people suffering from urinary incontinence. Int J Nurs Stud. Jun. 1999;36(3):245-53. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10404294].
2712 Roe B, Wilson K, Doll H. Public awareness and health education: findings from an evaluation of health services for incontinence in England. Int J Nurs Stud. Feb. 2001;38(1):79-89. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11137726].
2713 Roe BH. A comparison of nursing approaches for the promotion and management of continence in the U.K. and Denmark. Int J Nurs Stud. Feb. 1993;30(1):25-35. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8449656].
2714 Roehl B, Buchanan EM. Urinary incontinence evaluation and the utility of pessaries in older women. Care Management Journals. 2006;7(4):213-7. No associative hypothesis tested. [pmid: 17194058].
2715 Roehrborn CG, Abrams P, Rovner ES, et al. Efficacy and tolerability of tolterodine extended-release in men with overactive bladder and urgency urinary incontinence. BJU Int. May. 2006;97(5):1003-6. Not eligible target population. [pmid: 16643482].
2716 Roehrborn CG, Kaplan SA, Kraus SR, et al. Effects of serum PSA on efficacy of tolterodine extended release with or without tamsulosin in men with LUTS, including OAB. Urology. Nov. 2008;72(5):1061-7. discussion 7. Not eligible target population. [pmid: 18817961].
2717 Rogers CG, Su LM, Link RE, et al. Age stratified functional outcomes after laparoscopic radical prostatectomy. J Urol. Dec. 2006;176(6 Pt 1):2448-52. Not eligible target population. [pmid: 17085126].
2718 Rogers J. Care pathways for paediatric continence. Nurs Times. Jun 27-Jul 3. 2006;102(26):51. Not eligible target population. [pmid: 16845820].
2719 Rogers MA, Mody L, Kaufman SR, et al. Use of urinary collection devices in skilled nursing facilities in five states. Journal of the American Geriatrics Society. May. 2008;56(5):854-61. Not eligible target population. [pmid: 18454750].
2720 Rogers RG, Coates KW, Kammerer-Doak D, et al. A short form of the Pelvic Organ Prolapse/Urinary Incontinence Sexual Questionnaire (PISQ-12). Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2003;14(3):164-8. discussion 8. Not eligible outcomes. [pmid: 12955337].
2721 Rogers RG, Kammerer-Doak D, Olsen A, et al. A randomized, double-blind, placebo-controlled comparison of the effect of nitrofurantoin monohydrate macrocrystals on the development of urinary tract infections after surgery for pelvic organ prolapse and/or stress urinary incontinence with suprapubic catheterization. Am J Obstet Gynecol. Jul. 2004;191(1):182-7. Not eligible exposure. [pmid: 15295362].
2722 Rogers RG, Leeman LM, Migliaccio L, et al. Does the severity of spontaneous genital tract trauma affect postpartum pelvic floor function?. Int Urogynecol J Pelvic Floor Dysfunct. Mar. 2008;19(3):429-35. Not eligible exposure. [pmid: 17896065].
2723 Romancik M, Lutter I, Goncalves F, et al. Valsalva leak point pressure predicts outcome after transobturator suburethral tape implantation--fact or fiction?. Bratisl Lek Listy. 2006;107(11–12):426-9. Not eligible exposure. [pmid: 17425159].
2724 Romero AA, Hardart A, Kobak W, et al. Validation of a Spanish version of the Pelvic Organ Prolapse Incontinence Sexual Questionnaire. Obstet Gynecol. Nov. 2003;102(5 Pt 1):1000-5. Not eligible outcomes. [pmid: 14672477].
2725 Romero Maroto J, Ortiz Gorraiz M, Prieto Chaparro L, et al. Transvaginal adjustable tape: an adjustable mesh for surgical treatment of female stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2008;19(8):1109-16. Not eligible exposure. [pmid: 18360735].
2726 Romero Reyes R, Gorbea Chavez V, Rodriguez Colorado S, et al. Reduce-Intensive Pelvic Floor Exercise Program Efficacy for the Treatment of Urinary Incontinence. Randomized Controlled Trial. Paper presented at: 34th Annual Meeting of the International Urogynecological Association. Villa Erba, Como. 16–20 Jun 2009. Not eligible outcomes.
2727 Rondorf-Klym LM, Colling J. Quality of life after radical prostatectomy. Oncol Nurs Forum. Mar–Apr. 2003;30(2):E24-32. Not eligible target population. [pmid: 12692667].
2728 Roovers JP, van der Vaart CH, van der Bom JG, et al. A randomised controlled trial comparing abdominal and vaginal prolapse surgery: effects on urogenital function. BJOG. Jan. 2004;111(1):50-6. Not eligible exposure. [pmid: 14687052].
2729 Rose MA, Baigis-Smith J, Smith D, et al. Behavioral management of urinary incontinence in homebound older adults. Home Healthc Nurse. Sep–Oct. 1990;8(5):10-5. Not eligible target population. [pmid: 2243023].
2730 Ross J. Two techniques of laparoscopic Burch repair for stress incontinence: a prospective, randomized study. J Am Assoc Gynecol Laparosc. May. 1996;3(3):351-7. Not eligible exposure. [pmid: 9050655].
2731 Ross JW, Galen DI, Abbott K, et al. A prospective multisite study of radiofrequency bipolar energy for treatment of genuine stress incontinence. J Am Assoc Gynecol Laparosc. Nov. 2002;9(4):493-9. Not eligible exposure. [pmid: 12386362].
2732 Ross S, Robert M, Swaby C, et al. Transobturator tape compared with tension-free vaginal tape for stress incontinence: a randomized controlled trial. Obstet Gynecol. Dec. 2009;114(6):1287-94. Not eligible exposure. [pmid: 19935032].
2733 Rossignol G, Leandri P, Gautier JR, et al. Radical retropubic prostatectomy: complications and quality of life (429 cases, 1983–1989. Eur Urol. 1991;19(3):186-91. Not eligible target population. [pmid: 1855524].
2734 Roumeguere T, Quackels T, Bollens R, et al. Trans-obturator vaginal tape (TOT) for female stress incontinence: one year follow-up in 120 patients. Eur Urol. Nov. 2005;48(5):805-9. Not eligible exposure. [pmid: 16182440].
2735 Rovner ES, Kreder K, Sussman DO, et al. Effect of tolterodine extended release with or without tamsulosin on measures of urgency and patient reported outcomes in men with lower urinary tract symptoms. J Urol. Sep. 2008;180(3):1034-41. Not eligible target population. [pmid: 18639297].
2736 Rovner ES, Rackley R, Nitti VW, et al. Tolterodine extended release is efficacious in continent and incontinent subjects with overactive bladder. Urology. Sep. 2008;72(3):488-93. Not eligible target population. [pmid: 18639327].
2737 Roy S. The cost of continence. Elder Care. 1997 Dec–1998 Jan. 9(6 Suppl):3-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9511659].
2738 Roy S. Continence. Services for a new century. Nurs Times. Oct. 20–26. 1999;95(42):65-7. Not eligible exposure. [pmid: 10788893].
2739 Rubenstein LZ, Alessi CA, Josephson KR, et al. A randomized trial of a screening, case finding, and referral system for older veterans in primary care. Journal of the American Geriatrics Society. Feb. 2007;55(2):166-74. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17302651].
2740 Ruff CC. Risk factors for urinary incontinence in African-American women. Urol Nurs. Feb. 2005;25(1):33-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15779690].
2741 Ruiz-Deya G, Davis R, Srivastav SK, et al. Outpatient radical prostatectomy: impact of standard perineal approach on patient outcome. J Urol. Aug. 2001;166(2):581-6. Not eligible target population. [pmid: 11458072].
2742 Rutman M, Itano N, Deng D, et al. Long-term durability of the distal urethral polypropylene sling procedure for stress urinary incontinence: minimum 5-year followup of surgical outcome and satisfaction determined by patient reported questionnaires. J Urol. Feb. 2006;175(2):610-3. Not eligible exposure. [pmid: 16407006].
2743 Rutman MP, Deng DY, Shah SM, et al. Spiral sling salvage anti-incontinence surgery in female patients with a nonfunctional urethra: technique and initial results. J Urol. May. 2006;175(5):1794-8. discussion 8–9. Not eligible exposure. [pmid: 16600764].
2744 Ryan A, McFadden L. Timely intervention. Nurs Times. Aug. 16–22. 1995;91(33):56-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7667134].
2745 Saadoun K, Ringa V, Fritel X, et al. Negative impact of urinary incontinence on quality of life, a cross-sectional study among women aged 49–61 years enrolled in the GAZEL cohort. Neurourol Urodyn. 2006;25(7):696-702. Not eligible exposure. [pmid: 16917934].
2746 Saarni SI, Harkanen T, Sintonen H, et al. The impact of 29 chronic conditions on health-related quality of life: a general population survey in Finland using 15D and EQ-5D. Qual Life Res. Oct. 2006;15(8):1403-14. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16960751].
2747 Saban R, Saban MR, Nguyen NB, et al. Neurokinin-1 (NK-1) receptor is required in antigen-induced cystitis. Am J Pathol. Mar. 2000;156(3):775-80. Not eligible exposure. [pmid: 10702392].
2748 Sacco E, Prayer-Galetti T, Pinto F, et al. Urinary incontinence after radical prostatectomy: incidence by definition, risk factors and temporal trend in a large series with a long-term follow-up. BJU Int. Jun. 2006;97(6):1234-41. Not eligible target population. [pmid: 16686718].
2749 Sachse R. Pharmacodynamics and pharmacokinetics of ascending multiple oral doses of the novel bladder-selective antimuscarinic fesoterodine [abstract #111]. Eur Urol Suppl. 2003;43(Suppl 2):30. Not eligible outcomes.
2750 Sachse R, Cawello W, Haag-Molkenteller C, et al. Dose-proportional pharmacokinetics of the new antimuscarinic fesoterodine [abstract]. Arch Pharmacol. 2003;367(Suppl 1):446. Not eligible outcomes.
2751 Sackett CK. Spina bifida. Part 3. Implications for bladder and bowel management. Urol Nurs. Dec. 1993;13(4):104-6. Not eligible target population. [pmid: 8290995].
2752 Sackley CM, Rodriguez NA, van den Berg M, et al. A phase II exploratory cluster randomized controlled trial of a group mobility training and staff education intervention to promote urinary continence in UK care homes. Clin Rehabil. Aug. 2008;22(8):714-21. Not eligible target population. [pmid: 18678571].
2753 Safarinejad MR, Hosseini SY. Safety and efficacy of tramadol in the treatment of idiopathic detrusor overactivity: a double-blind, placebo-controlled, randomized study. Br J Clin Pharmacol. Apr. 2006;61(4):456-63. Not eligible exposure. [pmid: 16542207].
2754 Sahai A, Dowson C, Khan MS, et al. Repeated injections of botulinum toxin-A for idiopathic detrusor overactivity. Urology. Mar. 2010;75(3):552-8. Not eligible target population. [pmid: 20035984].
2755 Sahai A, Kalsi V, Khan MS, et al. Techniques for the intradetrusor administration of botulinum toxin. BJU Int. Apr. 2006;97(4):675-8. Not eligible exposure. [pmid: 16536751].
2756 Sahai A, Khan MS, Dasgupta P. Efficacy of botulinum toxin-A for treating idiopathic detrusor overactivity: results from a single center, randomized, double-blind, placebo controlled trial. J Urol. Jun. 2007;177(6):2231-6. Not eligible target population. [pmid: 17509328].
2757 Saigal CS, Gornbein J, Reid K, et al. Stability of time trade-off utilities for health states associated with the treatment of prostate cancer. Qual Life Res. Aug. 2002;11(5):405-14. Not eligible target population. [pmid: 12113388].
2758 Saint S, Kaufman SR, Rogers MA, et al. Condom versus indwelling urinary catheters: a randomized trial. J Am Geriatr Soc. Jul. 2006;54(7):1055-61. Not eligible exposure. [pmid: 16866675].
2759 Saint S, Lipsky BA, Baker PD, et al. Urinary catheters: what type do men and their nurses prefer?. J Am Geriatr Soc. Dec. 1999;47(12):1453-7. Not eligible target population. [pmid: 10591242].
2760 Saito M, Kawatani M, Kinoshita Y, et al. Effectiveness of an anti-inflammatory drug, loxoprofen, for patients with nocturia. Int J Urol. Aug. 2005;12(8):779-82. Not eligible target population. [pmid: 16174058].
2761 Saito M, Watanabe T, Tabuchi F, et al. Urodynamic effects and safety of modified intravesical oxybutynin chloride in patients with neurogenic detrusor overactivity: 3 years experience. Int J Urol. Aug. 2004;11(8):592-6. Not eligible exposure. [pmid: 15285747].
2762 Saito S, Namiki S, Numahata K, et al. Relevance of postcatheter removal incontinence to postoperative urinary function after radical prostatectomy. Int J Urol. Sep. 2006;13(9):1191-6. Not eligible target population. [pmid: 16984551].
2763 Sajadi KP, Goldman HB. Percutaneous tibial nerve stimulation and overactive bladder. Curr Urol Rep. Sep. 2010;11(5):293-5. Comment. [pmid: 20567947].
2764 Sakakibara R, Shinotoh H, Uchiyama T, et al. Questionnaire-based assessment of pelvic organ dysfunction in Parkinson’s disease. Auton Neurosci. Sep. 17. 2001;92(1–2):76-85. Not eligible target population. [pmid: 11570707].
2765 Sakamoto K, Sharma S, Wheeler JS. Long-term subjective continence status and use of alternative treatments by women with stress urinary incontinence after collagen injection therapy. World journal of urology. Aug. 2007;25(4):431-3. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17593370].
2766 Sakuragi N, Todo Y, Kudo M, et al. A systematic nerve-sparing radical hysterectomy technique in invasive cervical cancer for preserving postsurgical bladder function. Int J Gynecol Cancer. Mar–Apr. 2005;15(2):389-97. Not eligible target population. [pmid: 15823132].
2767 Saleh N, Bener A, Khenyab N, et al. Prevalence, awareness and determinants of health care-seeking behaviour for urinary incontinence in Qatari women: a neglected problem?. Maturitas. Jan. 10. 2005;50(1):58-65. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15590215].
2768 Saliba D, Solomon D, Rubenstein L, et al. Feasibility of quality indicators for the management of geriatric syndromes in nursing home residents. J Am Med Dir Assoc. Sep–Oct. 2004;5(5):310-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15357888].
2769 Salin A, Conquy S, Elie C, et al. Identification of risk factors for voiding dysfunction following TVT placement. Eur Urol. Mar. 2007;51(3):782-7. discussion 7. Not eligible exposure. [pmid: 17098355].
2770 Salle JL, McLorie GA, Bagli DJ, et al. Modifications of and extended indications for the Pippi Salle procedure. World J Urol. 1998;16(4):279-84. Not eligible exposure. [pmid: 9775428].
2771 Salomon L, Anastasiadis A, Saint F, et al. Introducing a new, simple scoring system to evaluate oncological and functional outcome after radical prostatectomy. Scand J Urol Nephrol. 2003;37(5):392-5. Not eligible target population. [pmid: 14594687].
2772 Salomon L, Saint F, Anastasiadis AG, et al. Combined reporting of cancer control and functional results of radical prostatectomy. Eur Urol. Dec. 2003;44(6):656-60. Not eligible target population. [pmid: 14644116].
2773 Saltvedt I, Mo ES, Fayers P, et al. Reduced mortality in treating acutely sick, frail older patients in a geriatric evaluation and management unit. A prospective randomized trial. J Am Geriatr Soc. May. 2002;50(5):792-8. Not eligible target population. [pmid: 12028163].
2774 Salvatore S, Khullar V, Anders K, et al. Reducing artefacts in ambulatory urodynamics. Br J Urol. Feb. 1998;81(2):211-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9488060].
2775 Salvesen KA, Morkved S. Randomised controlled trial of pelvic floor muscle training during pregnancy. BMJ. Aug. 14. 2004;329(7462):378-80. Not eligible target population. [pmid: 15253920].
2776 Samil RS, Wishnuwardhani SD. Health of Indonesian women city-dwellers of perimenopausal age. Maturitas. Oct. 1994;19(3):191-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7799825].
2777 Sammour ZM, Gomes CM, Duarte RJ, et al. Voiding dysfunction and the Williams-Beuren syndrome: a clinical and urodynamic investigation. J Urol. Apr. 2006;175(4):1472-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16516025].
2778 Sampselle CM. Behavioral interventions in young and middle-age women: simple interventions to combat a complex problem. Am J Nurs. Mar. 2003;(Suppl):9-19. Not eligible review. [pmid: 12612489].
2779 Sampselle CM. Teaching women to use a voiding diary. Am J Nurs. Nov. 2003;103(11):62-4. Not eligible outcomes. [pmid: 14625427].
2780 Sampselle CM, Harlow SD, Skurnick J, et al. Urinary incontinence predictors and life impact in ethnically diverse perimenopausal women. Obstet Gynecol. Dec. 2002;100(6):1230-8. not eligible outcomes. [pmid: 12468167].
2781 Sampselle CM, Messer KL, Seng JS, et al. Learning outcomes of a group behavioral modification program to prevent urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Nov–Dec. 2005;16(6):441-6. Not eligible target population. [pmid: 16237512].
2782 Sampselle CM, Miller JM, Luecha Y, et al. Provider support of spontaneous pushing during the second stage of labor. J Obstet Gynecol Neonatal Nurs. Nov–Dec. 2005;34(6):695-702. Not eligible target population. [pmid: 16282227].
2783 Sampselle CM, Wyman JF, Thomas KK, et al. Continence for women: a test of AWHONN’s evidence-based protocol in clinical practice. Association of Women’s Health Obstetric and Neonatal Nurses. J Obstet Gynecol Neonatal Nurs. Jan–Feb. 2000;29(1):18-26. Not eligible outcomes. [pmid: 10660273].
2784 Samuelsson E, Victor A, Svardsudd K. Determinants of urinary incontinence in a population of young and middle-aged women. Acta Obstet Gynecol Scand. Mar. 2000;79(3):208-15. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10716302].
2785 Samuelsson E, Victor A, Tibblin G. A population study of urinary incontinence and nocturia among women aged 20–59 years. Prevalence, well-being and wish for treatment. Acta Obstet Gynecol Scand. Jan. 1997;76(1):74-80. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9033249].
2786 Samuelsson EC, Victor FT, Svardsudd KF. Five-year incidence and remission rates of female urinary incontinence in a Swedish population less than 65 years old. Am J Obstet Gynecol. Sep. 2000;183(3):568-74. Not eligible target population. [pmid: 10992175].
2787 Sanchez-Ortiz RF, Broderick GA, Chaikin DC, et al. Collagen injection therapy for post-radical retropubic prostatectomy incontinence: role of Valsalva leak point pressure. J Urol. Dec. 1997;158(6):2132-6. Not eligible target population. [pmid: 9366329].
2788 Sand PK, Appell R. Disruptive effects of overactive bladder and urge urinary incontinence in younger women. Am J Med. Mar. 2006;119(3 Suppl 1):16-23. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16483864].
2789 Sand PK, Winkler H, Blackhurst DW, et al. A prospective randomized study comparing modified Burch retropubic urethropexy and suburethral sling for treatment of genuine stress incontinence with low-pressure urethra. Am J Obstet Gynecol. Jan. 2000;182(1 Pt 1):30-4. Not eligible exposure. [pmid: 10649153].
2790 Sanda MG, Dunn RL, Michalski J, et al. Quality of life and satisfaction with outcome among prostate-cancer survivors. N Engl J Med. Mar. 20. 2008;358(12):1250-61. Not eligible target population. [pmid: 18354103].
2791 Sander P, Mouritsen L, Andersen JT, et al. Evaluation of a simple, non-surgical concept for management of urinary incontinence (minimal care) in an open-access, interdisciplinary incontinence clinic. Neurourol Urodyn. 2000;19(1):9-17. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10602244].
2792 Sanderson KM, Penson DF, Cai J, et al. Salvage radical prostatectomy: quality of life outcomes and long-term oncological control of radiorecurrent prostate cancer. J Urol. Nov. 2006;176(5):2025-31. discussion 31–2. Not eligible target population. [pmid: 17070244].
2793 Sandvik H, Hunskaar S. Incontinence in women: different response rates may introduce bias in community studies of pad consumption. J Epidemiol Community Health. Aug. 1994;48(4):419. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7964344].
2794 Sandvik H, Hunskaar S. The epidemiology of pad consumption among community-dwelling incontinent women. J Aging Health. Aug. 1995;7(3):417-26. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10165973].
2795 Sandvik H, Kveine E, Hunskaar S. Female urinary incontinence--psychosocial impact, self care, and consultations. Scand J Caring Sci. 1993;7(1):53-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8502856].
2796 Sange C, Thomas L, Lyons C, et al. Urinary incontinence in Muslim women. Nurs Times. Jun. 24–30. 2008;104(25):49-52. Not eligible exposure. [pmid: 18672845].
2797 Santaniello F, Giannantoni A, Cochetti G, et al. Body mass index and lower urinary tract symptoms in women. Arch Ital Urol Androl. Mar. 2007;79(1):17-9. Not eligible target population. [pmid: 17484398].
2798 Santarosa RP, Blaivas JG. Periurethral injection of autologous fat for the treatment of sphincteric incontinence. J Urol. Mar. 1994;151(3):607-11. Not eligible target population. [pmid: 8308969].
2799 Santis WF, Hoffman MA, Dewolf WC. Early catheter removal in 100 consecutive patients undergoing radical retropubic prostatectomy. BJU Int. Jun. 2000;85(9):1067-8. Not eligible target population. [pmid: 10848696].
2800 Santoro G, Wieczorek P, Shobeiri SA, et al. Interobserver and interdisciplinary reliability of 3D endovaginal ultrasound assessment of pelvic floor anatomy. Paper presented at: Neurourology and Urodynamics, 2010; Joint Meeting of the International Continence Society and the International Urogynecological Association. Toronto, Canada. 23–27 August 2010. Not eligible target population.
2801 Sartore A, De Seta F, Maso G, et al. The effects of mediolateral episiotomy on pelvic floor function after vaginal delivery. Obstetrics and gynecology. 2004;(4):669-73. Not eligible exposure. [pmid: 15051557].
2802 Sartori MG, Baracat EC, Girao MJ, et al. Menopausal genuine stress urinary incontinence treated with conjugated estrogens plus progestogens. Int J Gynaecol Obstet. May. 1995;49(2):165-9. Not eligible exposure. [pmid: 7649322].
2803 Saxer S, de Bie RA, Dassen T, et al. Nurses’ knowledge and practice about urinary incontinence in nursing home care. Nurse education today. Nov. 2008;28(8):926-34. Not eligible target population. [pmid: 18582993].
2804 Schafer JW, Welzel G, Trojan L, et al. Long-term health-related quality-of-life outcomes after permanent prostate brachytherapy. Onkologie. Nov. 2008;31(11):599-603. Not eligible target population. [pmid: 19145092].
2805 Schaffer JI, Bloom SL, Casey BM, et al. A randomized trial of the effects of coached vs uncoached maternal pushing during the second stage of labor on postpartum pelvic floor structure and function. Am J Obstet Gynecol. May. 2005;192(5):1692-6. Not eligible target population. [pmid: 15902179].
2806 Scheepens WA, Van Koeveringe GA, De Bie RA, et al. Long-term efficacy and safety results of the two-stage implantation technique in sacral neuromodulation. BJU Int. Dec. 2002;90(9):840-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12460343].
2807 Scheer I, Andrews V, Thakar R, et al. Urinary incontinence after obstetric anal sphincter injuries (OASIS)--is there a relationship?. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2008;19(2):179-83. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17671753].
2808 Schettini M, Diana M, Gallucci M. Treatment of urinary incontinence with AMS800 artificial urinary sphincter. Int Surg. Jul–Sep. 1998;83(3):257-61. Not eligible exposure. [pmid: 9870787].
2809 Schierlitz L, Dwyer PL, Rosamilia A, et al. Effectiveness of tension-free vaginal tape compared with transobturator tape in women with stress urinary incontinence and intrinsic sphincter deficiency: a randomized controlled trial. Obstet Gynecol. Dec. 2008;112(6):1253-61. Not eligible exposure. [pmid: 19037033].
2810 Schiotz HA. One month maximal electrostimulation for genuine stress incontinence in women. Neurourol Urodyn. 1994;13(1):43-50. Level of evidence. [pmid: 8156074].
2811 Schiøtz HA. Comparison of 1 and 3 days’ transurethral Foley catheterization after retropubic incontinence surgery. International urogynecology journal and pelvic floor dysfunction. 1996:98-101. Not eligible exposure. [pmid: 8798095].
2812 Schiotz HA, Karlsen JH, Tanbo TG. Ten-year follow-up after conservative treatment of stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Jul. 2008;19(7):911-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18188487].
2813 Schirm V, Baumgardner J, Dowd T, et al. Development of a healthy bladder education program for older adults. Geriatr Nurs. Sep–Oct. 2004;25(5):301-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15486549].
2814 Schlarp O, Huebner WA. Single Centre Austrian Study Evaluating the Adjustable Continence Therapy (Proact) for Male Post Prostatectomy Stress Urinary Incontinence- Last 17 Months Follow Up. Paper presented at: 21st Annual Congress of the European Association of Urology (EAU 2006), Palais des Congres. Paris (France). 5–8 Apr 2006. Not eligible target population.
2815 Schlenk EA, Erlen JA, Dunbar-Jacob J, et al. Health-related quality of life in chronic disorders: a comparison across studies using the MOS SF-36. Qual Life Res. Jan. 1998;7(1):57-65. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9481151].
2816 Schlenker B, Gratzke C, Reich O, et al. Preliminary results on the off-label use of duloxetine for the treatment of stress incontinence after radical prostatectomy or cystectomy. Eur Urol. Jun. 2006;49(6):1075-8. Not eligible target population. [pmid: 16481094].
2817 Schmidt AP, Sanches PR, Silva DP Jr, et al. A new pelvic muscle trainer for the treatment of urinary incontinence. Int J Gynaecol Obstet. Jun. 2009;105(3):218-22. Not eligible exposure. [pmid: 19232601].
2818 Schmidt RA, Jonas U, Oleson KA, et al. Sacral nerve stimulation for treatment of refractory urinary urge incontinence. Sacral Nerve Stimulation Study Group. J Urol. Aug. 1999;162(2):352-7. Not eligible exposure. [pmid: 10411037].
2819 Schneider T, Sperling H, Rossi R, et al. Do early injections of bulking agents following radical prostatectomy improve early continence?. World J Urol. Nov. 2005;23(5):338-42. Not eligible target population. [pmid: 16261366].
2820 Schnelle JF. Treatment of urinary incontinence in nursing home patients by prompted voiding. Journal of the American Geriatrics Society. 1990;38(3):356-60. Not eligible target population. [pmid: 2313014].
2821 Schnelle JF, Alessi CA, Al-Samarrai NR, et al. The nursing home at night: effects of an intervention on noise, light, and sleep. J Am Geriatr Soc. Apr. 1999;47(4):430-8. Not eligible target population. [pmid: 10203118].
2822 Schnelle JF, Kapur K, Alessi C, et al. Does an exercise and incontinence intervention save healthcare costs in a nursing home population?. J Am Geriatr Soc. Feb. 2003;51(2):161-8. Not eligible target populaion. [pmid: 12558711].
2823 Schnelle JF, Keeler E, Hays RD, et al. A cost and value analysis of two interventions with incontinent nursing home residents. J Am Geriatr Soc. Oct. 1995;43(10):1112-7. Not eligible target population. [pmid: 7560701].
2824 Schnelle JF, Leung FW. Urinary and Fecal Incontinence in Nursing Homes. Gastroenterology. 2004;126(1). Not eligible target population.
2825 Schnelle JF, MacRae PG, Ouslander JG, et al. Functional Incidental Training, mobility performance, and incontinence care with nursing home residents. J Am Geriatr Soc. Dec. 1995;43(12):1356-62. Not eligible target population. [pmid: 7490386].
2826 Schnelle JF, Ouslander JG, Cruise PA. Policy without technology: a barrier to improving nursing home care. Gerontologist. Aug. 1997;37(4):527-32. Not eligible target population. [pmid: 9279042].
2827 Schnelle JF, Ouslander JG, Osterweil D, et al. Total quality management: administrative and clinical applications in nursing homes. J Am Geriatr Soc. Nov. 1993;41(11):1259-66. Not eligible target population. [pmid: 8227902].
2828 Schnelle JF, Ouslander JG, Simmons SF, et al. The nighttime environment, incontinence care, and sleep disruption in nursing homes. J Am Geriatr Soc. Sep. 1993;41(9):910-4. Not eligible target population. [pmid: 8409176].
2829 Schoeggl A, Reddy M, Matula C. Neurological outcome following laminectomy in spinal metastases. Spinal Cord. Jul. 2002;40(7):363-6. Not eligible target population. [pmid: 12080464].
2830 Schraffordt Koops SE, Bisseling TM, Heintz AP, et al. Prospective analysis of complications of tension-free vaginal tape from The Netherlands Tension-free Vaginal Tape study. American Journal of Obstetrics & Gynecology. Jul. 2005;193(1):45-52. Not eligible exposure. [pmid: 16021057].
2831 Schraffordt Koops SE, Bisseling TM, Heintz AP, et al. Quality of life before and after TVT, a prospective multicentre cohort study, results from the Netherlands TVT database. BJOG. Jan. 2006;113(1):26-9. Not eligible exposure. [pmid: 16398767].
2832 Schraffordt Koops SE, Bisseling TM, Heintz AP, et al. The effectiveness of tension-free vaginal tape (TVT) and quality of life measured in women with previous urogynecologic surgery: analysis from The Netherlands TVT database. Am J Obstet Gynecol. Aug. 2006;195(2):439-44. Not eligible exposure. [pmid: 16635472].
2833 Schraffordt Koops SE, Bisseling TM, van Brummen HJ, et al. Result of the tension-free vaginal tape in patients with concomitant prolapse surgery: a 2-year follow-up study. An analysis from the Netherlands TVT database. Int Urogynecol J Pelvic Floor Dysfunct. Apr. 2007;18(4):437-42. Not eligible exposure. [pmid: 16909194].
2834 Schulte-Baukloh H, Knispel HH, Stolze T, et al. Repeated botulinum-A toxin injections in treatment of children with neurogenic detrusor overactivity. Urology. Oct. 2005;66(4):865-70. discussion 70. Not eligible target population. [pmid: 16230156].
2835 Schulte-Baukloh H, Murtz G, Henne T, et al. Urodynamic effects of propiverine hydrochloride in children with neurogenic detrusor overactivity: a prospective analysis. BJU Int. Feb. 2006;97(2):355-8. Not eligible target population. [pmid: 16430646].
2836 Schulte-Baukloh H, Thalau F, Sturzebecher B, et al. Pubovaginal bone anchor fixation with polyethylene versus fascia lata slings in the treatment of female stress incontinence: sling material and processing are predominant factors in success. Can J Urol. Apr. 2005;12(2):2581-7. Not eligible exposure. [pmid: 15877939].
2837 Schulte-Baukloh H, Weiss C, Schobert J, et al. Subjective patient satisfaction after injection of botulinum-a toxin in detrusor overactivity. Aktuelle Urol. Jun. 2005;36(3):230-3. Not eligible language. [pmid: 16001338].
2838 Schultz SE, Kopec JA. Impact of chronic conditions. Health Rep. Aug. 2003;14(4):41-53. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14608795].
2839 Schurch B, de Seze M, Denys P, et al. Botulinum toxin type a is a safe and effective treatment for neurogenic urinary incontinence: results of a single treatment, randomized, placebo controlled 6-month study. J Urol. Jul. 2005;174(1):196-200. Not eligible target population. [pmid: 15947626].
2840 Schurch B, Denys P, Kozma CM, et al. Botulinum toxin A improves the quality of life of patients with neurogenic urinary incontinence. Eur Urol. Sep. 2007;52(3):850-8. Not eligible target population. [pmid: 17467889].
2841 Schuster TG, Marcovich R, Sheffield J, et al. Radical cystectomy for bladder cancer after definitive prostate cancer treatment. Urology. Feb. 2003;61(2):342-7. discussion 7. Not eligible target population. [pmid: 12597943].
2842 Schweitzer K, Daan N, vd Vaart H. The association between frequency as a subjective symptom and objective findings on bladder diaries and urodynamic investigation. Paper presented at: Neurourology and Urodynamics, 2010; Joint Meeting of the International Continence Society and the International Urogynecological Association. Toronto, Canada. 23–27 August 2010. Not eligible outcomes.
2843 Schweitzer KJ, Vierhout ME, Milani AL. Surgery for pelvic organ prolapse in women of 80 years of age and older. Acta Obstet Gynecol Scand. Mar. 2005;84(3):286-9. Not eligible exposure. [pmid: 15715538].
2844 Scott D. Continence. Bangladeshi venture. Nurs Times. Oct. 20–26. 1999;95(42):76-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10788896].
2845 Sears CL, Wright J, O’Brien J, et al. The racial distribution of female pelvic floor disorders in an equal access health care system. J Urol. Jan. 2009;181(1):187-92. Not eligible target population. [pmid: 19013607].
2846 Sebesta M, Cespedes RD, Luhman E, et al. Questionnaire-based outcomes of urinary incontinence and satisfaction rates after radical prostatectomy in a national study population. Urology. Dec. 2002;60(6):1055-8. Not eligible target population. [pmid: 12475669].
2847 Seckiner I, Yesilli C, Mungan NA, et al. Correlations between the ICIQ-SF score and urodynamic findings. Neurourol Urodyn. 2007;26(4):492-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17304520].
2848 Segal J, Steele A, Vassallo B, et al. Various surgical approaches to treat voiding dysfunction following anti-incontinence surgery. Int Urogynecol J Pelvic Floor Dysfunct. Jun. 2006;17(4):372-7. Not eligible exposure. [pmid: 16429244].
2849 Segal JL, Vassallo B, Kleeman S, et al. Prevalence of persistent and de novo overactive bladder symptoms after the tension-free vaginal tape. Obstet Gynecol. Dec. 2004;104(6):1263-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15572487].
2850 Seim A, Hermstad R, Hunskaar S. Female urinary incontinence: long-term follow-up after treatment in general practice. Br J Gen Pract. Nov. 1998;48(436):1731-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10198478].
2851 Seim A, Sandvik H, Hermstad R, et al. Female urinary incontinence--consultation behaviour and patient experiences: an epidemiological survey in a Norwegian community. Fam Pract. Mar. 1995;12(1):18-21. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7665034].
2852 Seim A, Sivertsen B, Eriksen BC, et al. Treatment of urinary incontinence in women in general practice: observational study. BMJ. Jun. 8. 1996;312(7044):1459-62. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8664627].
2853 Seki N, Mochida O, Kinukawa N, et al. Holmium laser enucleation for prostatic adenoma: analysis of learning curve over the course of 70 consecutive cases. J Urol. Nov. 2003;170(5):1847-50. Not eligible target population. [pmid: 14532790].
2854 Seki N, Tatsugami K, Naito S. Holmium laser enucleation of the prostate: comparison of outcomes according to prostate size in 97 Japanese patients. J Endourol. Feb. 2007;21(2):192-6. Not eligible target population. [pmid: 17338621].
2855 Selli C, De Antoni P, Moro U, et al. Role of bladder neck preservation in urinary continence following radical retropubic prostatectomy. Scand J Urol Nephrol. 2004;38(1):32-7. Not eligible target population. [pmid: 15204424].
2856 Sen I, Onaran M, Aksakal N, et al. The impact of urinary incontinence on female sexual function. Adv Ther. Nov–Dec. 2006;23(6):999-1008. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17276967].
2857 Senior J. Clean intermittent self-catheterisation and children. Br J Community Nurs. Aug. 2001;6(8):381-6. Not eligible target population. [pmid: 11865205].
2858 Serati M, Salvatore S, Uccella S, et al. Urinary incontinence at orgasm: relation to detrusor overactivity and treatment efficacy. Eur Urol. Oct. 2008;54(4):911-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18036728].
2859 Serels S. Solifenacin in overactive bladder syndrome: a viewpoint by Scott Serels. Drugs Aging. 2005;22(12):1070-1. Comment. [pmid: 16363888].
2860 Serels S, Stein M. Prospective study comparing hyoscyamine, doxazosin, and combination therapy for the treatment of urgency and frequency in women. Neurourol Urodyn. 1998;17(1):31-6. Not eligible exposure. [pmid: 9453690].
2861 Serra DB, Affrime MB, Bedigian MP, et al. QT and QTc interval with standard and supratherapeutic doses of darifenacin, a muscarinic M3 selective receptor antagonist for the treatment of overactive bladder. J Clin Pharmacol. Sep. 2005;45(9):1038-47. Not eligible exposure. [pmid: 16100298].
2862 Seveso M, Ceresoli A, Zanetti G, et al. Bladder training in patients with urinary incontinence in prostatic post-adenomectomy and TURP. IL BLADDER TRAINING NEL PAZIENTE INCONTINENTE POST ADENOMECTOMIA PROSTATICA E TURP. 1993;7(SUPPL 2):167-8. Not eligible target population.
2863 Sevestre S, Ciofu C, Deval B, et al. Results of the tension-free vaginal tape technique in the elderly. Eur Urol. Jul. 2003;44(1):128-31. Not eligible exposure. [pmid: 12814688].
2864 Sgadari A, Topinkova E, Bjornson J, et al. Urinary incontinence in nursing home residents: a cross-national comparison. Age Ageing. Sep. 1997;26(Suppl 2):49-54. Not eligible target population. [pmid: 9464555].
2865 Shafik A. Straining puborectalis reflex: Description and significance of a “new” reflex. Anatomical Record. 1991:281-4. Not eligible target population. [pmid: 2012316].
2866 Shafik A, Shafik IA. Overactive bladder inhibition in response to pelvic floor muscle exercises. World journal of urology. 2003:374-7. Not eligible target population. [pmid: 12682771].
2867 Shah PN, Maly RC, Frank JC, et al. Managing geriatric syndromes: what geriatric assessment teams recommend, what primary care physicians implement, what patients adhere to. J Am Geriatr Soc. Apr. 1997;45(4):413-9. Not eligible target population. [pmid: 9100708].
2868 Shahin AY, Hameed DA. Does visceral peritoneal closure affect post-cesarean urinary symptoms? A randomized clinical trial. Int Urogynecol J Pelvic Floor Dysfunct. Jan. 2010;21(1):33-41. Not eligible target population. [pmid: 19771385].
2869 Shaker HS, Hassouna M. Sacral nerve root neuromodulation: an effective treatment for refractory urge incontinence. J Urol. May. 1998;159(5):1516-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9554345].
2870 Shakir YA, Samsioe G, Khatibi EA, et al. Health hazards in middle-aged women with cardiovascular disease: a case-control study of swedish women the women’s health in the Lund area (WHILA) study. J Womens Health (Larchmt). Apr. 2007;16(3):406-14. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17439385].
2871 Sharifiaghdas F, Mortazavi N. Tension-free vaginal tape and autologous rectus fascia pubovaginal sling for the treatment of urinary stress incontinence: a medium-term follow-up. Med Princ Pract. 2008;17(3):209-14. Not eligible exposure. [pmid: 18408389].
2872 Sharma S, Albertazzi P, Bottazzi M. The long-term effect of raloxifene on the genitourinary tract. Climacteric. Jun. 2007;10(3):244-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17487651].
2873 Shaw C, Das Gupta R, Williams KS, et al. A survey of help-seeking and treatment provision in women with stress urinary incontinence. BJU Int. Apr. 2006;97(4):752-7. Not eligible exposure. [pmid: 16536767].
2874 Shaw C, Gupta RD, Bushnell DM, et al. The extent and severity of urinary incontinence amongst women in UK GP waiting rooms. Fam Pract. Oct. 2006;23(5):497-506. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16840498].
2875 Shaw C, Tansey R, Jackson C, et al. Barriers to help seeking in people with urinary symptoms. Fam Pract. Feb. 2001;18(1):48-52. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11145628].
2876 Shehu BB, Ameh EA, Ismail NJ. Spina bifida cystica: selective management in Zaria, Nigeria. Ann Trop Paediatr. Sep. 2000;20(3):239-42. Not eligible target population. [pmid: 11064780].
2877 Shelfo SW, Obek C, Soloway MS. Update on bladder neck preservation during radical retropubic prostatectomy: impact on pathologic outcome, anastomotic strictures, and continence. Urology. Jan. 1998;51(1):73-8. Not eligible target population. [pmid: 9457292].
2878 Shepherd BD, Merchant N, Fasig J, et al. Endoscopic ultrasound diagnosis of pelvic lipoma causing neurologic symptoms. Digestive Diseases & Sciences. Aug. 2006;51(8):1364-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16868819].
2879 Shepherd E. Lucky dip. Nurs Times. Jun. 4–10. 1997;93(23):34-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9205356].
2880 Sherman AM, Shumaker SA, Kancler C, et al. Baseline health-related quality of life in postmenopausal women with coronary heart disease: the Estrogen Replacement and Atherosclerosis (ERA) trial. J Womens Health (Larchmt). May. 2003;12(4):351-62. Not eligible target population. [pmid: 12804342].
2881 Sherman AM, Shumaker SA, Sharp P, et al. No effect of HRT on health-related quality of life in postmenopausal women with heart disease. Minerva Ginecol. Dec. 2003;55(6):511-7. Not eligible target population. [pmid: 14676740].
2882 Sherman FT. Functional assessment. Easy-to-use screening tools speed initial office work-up. Geriatrics. Aug. 2001;56(8):36-40. quiz 3. Not eligible exposure. [pmid: 11505859].
2883 Shifren JL, Monz BU, Russo PA, et al. Sexual problems and distress in United States women: prevalence and correlates. Obstet Gynecol. Nov. 2008;112(5):970-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18978095].
2884 Shih YC, Hartzema AG, Tolleson-Rinehart S. Labor costs associated with incontinence in long-term care facilities. Urology. Sep. 2003;62(3):442-6. Not eligible target population. [pmid: 12946743].
2885 Shimabukuro T, Naito K. Evaluation of lower urinary tract symptoms and how bothersome it was with or without urinary incontinence in apparently healthy persons of both sexes. Hinyokika Kiyo. Mar. 2007;53(3):157-62. Not eligible target population. [pmid: 17447483].
2886 Shimanouchi S, Kamei T, Hayashi M. Home care for the frail elderly based on urinary incontinence level. Public Health Nurs. Nov–Dec. 2000;17(6):468-73. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11115145].
2887 Shinopulos NM, Dann JA, Smith JJ 3rd. Patient selection and education for use of the CapSure (Re/Stor) continence shield. Urol Nurs. Jun. 1999;19(2):135-40. Not eligible exposure. [pmid: 10633764].
2888 Shinopulos NM, Jacobson J. Relationship between health promotion lifestyle profiles and patient outcomes of biofeedback therapy for urinary incontinence. Urol Nurs. Dec. 1999;19(4):249-53. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10889768].
2889 Short DD. Tolterodine, a new antimuscarinic drug for treatment of bladder overactivity--a comment. Pharmacotherapy. Oct. 1999;19(10):1188. Comment. [pmid: 10512072].
2890 Showalter PR, Zimmern PE, Roehrborn CG, et al. Standing cystourethrogram: an outcome measure after anti-incontinence procedures and cystocele repair in women. Urology. Jul. 2001;58(1):33-7. Not eligible exposure. [pmid: 11445475].
2891 Shukla A, Johnson D, Bibby J. Impact of patient position on filling phase of urodynamics in women. Int Urogynecol J Pelvic Floor Dysfunct. May. 2006;17(3):231-3. Not eligible exposure. [pmid: 16001131].
2892 Shukla AR, Pow-Sang JM, Helal MA, et al. Urinary incontinence after continent urinary diversion using cecal wrap or plicated ileum: a patient questionnaire review. Urology. Feb. 2003;61(2):328-31. Not eligible target population. [pmid: 12597940].
2893 Shultz JM. Urinary incontinence: solving a secret problem. Nursing. Nov. 2002;32(11 Pt 1):53-5. no primary result. [pmid: 12441858].
2894 Shuttleworth A. How the children’s national service framework affects continence care. Nurs Times. Nov 30–Dec 6. 2004;100(48):61. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15631398].
2895 Sibbald B. Unique health needs of elderly women being ignored, symposium told. CMAJ. Nov. 16. 1999;161(10):1309-10. no primary result. [pmid: 10584100].
2896 Siddiqui MA, Perry CM, Scott LJ. Oxybutynin extended-release: a review of its use in the management of overactive bladder. Drugs. 2004;64(8):885-912. Review. [pmid: 15059046].
2897 Siegel SW, Catanzaro F, Dijkema HE, et al. Long-term results of a multicenter study on sacral nerve stimulation for treatment of urinary urge incontinence, urgency-frequency, and retention. Urology. Dec. 4. 2000;56(6 Suppl 1):87-91. Not eligible exposure. [pmid: 11114569].
2898 Siegel SW, Richardson DA, Miller KL, et al. Pelvic floor electrical stimulation for the treatment of urge and mixed urinary incontinence in women. Urology. Dec. 1997;50(6):934-40. Level of evidence. [pmid: 9426726].
2899 Siegmund W, Sillen U, Lackgren G, et al. Pharmacokinetics and pharmacodynamics of propiverine in children aged between 5 and 10 years with symptoms of overactive bladder. Clin Pharmacokinet. May. 1. 2010;49(5):335-42. Not eligible target population. [pmid: 20384395].
2900 Siltberg H, Larsson G, Hallen B, et al. Validation of cough-induced leak point pressure measurement in the evaluation of pharmacological treatment of stress incontinence. Neurourology & Urodynamics. 1999:591-602. Not eligible exposure. [pmid: 10529707].
2901 Silva C, Silva J, Castro H, et al. Bladder sensory desensitization decreases urinary urgency. BMC Urol. 2007;7:9. Not eligible exposure. [pmid: 17561998].
2902 Silva C, Silva J, Ribeiro MJ, et al. Urodynamic effect of intravesical resiniferatoxin in patients with neurogenic detrusor overactivity of spinal origin: results of a double-blind randomized placebo-controlled trial. Eur Urol. Oct. 2005;48(4):650-5. Not eligible target population. [pmid: 15961217].
2903 Silva WA, Pauls RN, Segal JL, et al. Uterosacral ligament vault suspension: five-year outcomes. Obstet Gynecol. Aug. 2006;108(2):255-63. Not eligible exposure. [pmid: 16880293].
2904 Silva-Filho AL, Candido EB, Noronha A, et al. Comparative study of autologous pubovaginal sling and synthetic transobturator (TOT) SAFYRE sling in the treatment of stress urinary incontinence. Arch Gynecol Obstet. Feb. 2006;273(5):288-92. Not eligible exposure. [pmid: 16189692].
2905 Silver N, Sandage B, Sabounjian L, et al. Pharmacokinetics of once-daily trospium chloride 60 mg extended release and twice-daily trospium chloride 20 mg in healthy adults. J Clin Pharmacol. Feb. 2010;50(2):143-50. Not eligible target population. [pmid: 19948948].
2906 Silverman M, McDowell BJ, Musa D, et al. To treat or not to treat: issues in decisions not to treat older persons with cognitive impairment, depression, and incontinence. J Am Geriatr Soc. Sep. 1997;45(9):1094-101. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9288017].
2907 Simeone C. Clinical evaluation of urinary incontinence and pelvic prolapse: ICI flow-chart. Arch Ital Urol Androl. Mar. 2004;76(1):43-5. no primary result. [pmid: 15185824].
2908 Simeonova Z, Milsom I, Kullendorff AM, et al. The prevalence of urinary incontinence and its influence on the quality of life in women from an urban Swedish population. Acta Obstet Gynecol Scand. Jul. 1999;78(6):546-51. Not eligible exposure. [pmid: 10376867].
2909 Simmons SF, Ouslander JG. Resident and family satisfaction with incontinence and mobility care: sensitivity to intervention effects?. Gerontologist. Jun. 2005;45(3):318-26. Not eligible target population. [pmid: 15933272].
2910 Simmons SF, Schnelle JF. Strategies to measure nursing home residents’ satisfaction and preferences related to incontinence and mobility care: implications for evaluating intervention effects. Gerontologist. Jun. 1999;39(3):345-55. Not eligible target population. [pmid: 10396892].
2911 Simons AM, Dowell CJ, Bryant CM, et al. Use of the Dowell Bryant Incontinence Cost Index as a post-treatment outcome measure after non-surgical therapy. Neurourol Urodyn. 2001;20(1):85-93. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11135385].
2912 Singh BK, Masey H, Morton R. Levels of continence in children with cerebral palsy. Paediatr Nurs. May. 2006;18(4):23-6. Not eligible target population. [pmid: 16719038].
2913 Singh M, Bushman W, Clemens JQ. Do pad tests and voiding diaries affect patient willingness to participate in studies of incontinence treatment outcomes?. J Urol. Jan. 2004;171(1):316-8. discussion 8–9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14665904].
2914 Sinha D, Blackwell A, Moran PA. Outcome measures after TVT for mixed urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Jul. 2008;19(7):927-31. Not eligible exposure. [pmid: 18250947].
2915 Sink KM, Thomas J 3rd, Xu H, et al. Dual use of bladder anticholinergics and cholinesterase inhibitors: long-term functional and cognitive outcomes. Journal of the American Geriatrics Society. May. 2008;56(5):847-53. Not eligible target population. [pmid: 18384584].
2916 Siracusano S, Bertolotto M, Silvestre G, et al. The feasibility of urethral color ultrasound imaging in the diagnosis of female intrinsic sphincter deficiency: preliminary results. Spinal Cord. Apr. 2002;40(4):192-5. Not eligible outcomes. [pmid: 11965558].
2917 Sitoh YY, Lau TC, Zochling J, et al. Determinants of health-related quality of life in institutionalised older persons in northern Sydney. Intern Med J. Feb. 2005;35(2):131-4. Not eligible target population. [pmid: 15705146].
2918 Siu AL, Beers MH, Morgenstern H. The geriatric “medical and public health” imperative revisited. J Am Geriatr Soc. Jan. 1993;41(1):78-84. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8418128].
2919 Siu LS, Chang AM, Yip SK. Compliance with a pelvic muscle exercise program as a causal predictor of urinary stress incontinence amongst Chinese women. Neurourol Urodyn. 2003;22(7):659-63. Level of evidence. [pmid: 14595610].
2920 Sivanesan K, Fattah MA, Ramsay I. Transobturator tape as a day surgery procedure: a case control study. Int J Surg. Jun. 2007;5(3):152-4. Not eligible exposure. [pmid: 17509495].
2921 Sivaslioglu A, Dolen I, Yigitbasi S, et al. Vaginal Cones Stepfree in the Treatment of Mixt Stres Urinary Incontinence. Paper presented at: 31st Annual Meeting of the International Urogynecological Association. Athens Hilton Hotel, Athens (Greece). 6–9 Sep 2006. Not eligible outcomes.
2922 Sivaslioglu AA, Caliskan E, Dolen I, et al. A randomized comparison of transobturator tape and Burch colposuspension in the treatment of female stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2007;18(9):1015-9. Not eligible exposure. [pmid: 17180553].
2923 Sivaslioglu AA, Demir B, Dolen Y, et al. Residents performance in transobturator tape procedures for stress urinary incontinence. Eur J Obstet Gynecol Reprod Biol. Oct. 2007;134(2):259-61. Not eligible exposure. [pmid: 17258381].
2924 Sivaslioglu AA, Unlubilgin E, Dolen I. The multifilament polypropylene tape erosion trouble: tape structure vs surgical technique. Which one is the cause?. Int Urogynecol J Pelvic Floor Dysfunct. Mar. 2008;19(3):417-20. Not eligible exposure. [pmid: 17876489].
2925 Sivaslioglu AA, Unlubilgin E, Dolen I. A randomized comparison of polypropylene mesh surgery with site-specific surgery in the treatment of cystocoele. Int Urogynecol J Pelvic Floor Dysfunct. Apr. 2008;19(4):467-71. Not eligible exposure. [pmid: 17901910].
2926 Skeil D, Thorpe AC. Transcutaneous electrical nerve stimulation in the treatment of neurological patients with urinary symptoms. BJU Int. Dec. 2001;88(9):899-908. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11851611].
2927 Skelly J, Boblin-Cummings S. Promoting seniors’ health--confronting the issue of incontinence. Can J Nurs Leadersh. Sep–Oct. 1999;12(3):13-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11094934].
2928 Skilling PM, Petros P. Synergistic non-surgical management of pelvic floor dysfunction: second report. Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2004;15(2):106-10. discussion 10. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15014937].
2929 Skinner MH, Kuan HY, Pan A, et al. Duloxetine is both an inhibitor and a substrate of cytochrome P4502D6 in healthy volunteers. Clin Pharmacol Ther. Mar. 2003;73(3):170-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12621382].
2930 Skinner MH, Kuan HY, Skerjanec A, et al. Effect of age on the pharmacokinetics of duloxetine in women. Br J Clin Pharmacol. Jan. 2004;57(1):54-61. Not eligible outcomes. [pmid: 14678340].
2931 Skjeldestad FE, Hagen B. Long-term consequences of gynecological cancer treatment on urinary incontinence: a population-based cross-sectional study. Acta Obstet Gynecol Scand. 2008;87(4):469-75. Not eligible target population. [pmid: 18382876].
2932 Skjeldestad FE, Rannestad T. Urinary incontinence and quality of life in long-term gynecological cancer survivors: a population-based cross-sectional study. Acta Obstet Gynecol Scand. 2009;88(2):192-9. Not eligible target population. [pmid: 19031296].
2933 Skobejko-Wlodarska L. Treatment of neuropathic urinary and faecal incontinence. Eur J Pediatr Surg. Oct. 2002;12(5):318-21. Not eligible target population. [pmid: 12469258].
2934 Skoner MM. Self-management of urinary incontinence among women 31 to 50 years of age. Rehabil Nurs. Nov–Dec. 1994;19(6):339-43. 47. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7855400].
2935 Slack M, Culligan P, Tracey M, et al. Relationship of urethral retro-resistance pressure to urodynamic measurements and incontinence severity. Neurourol Urodyn. 2004;23(2):109-14. Not eligible outcomes. [pmid: 14983420].
2936 Sladden MJ, Hughes AM, Hirst GH, et al. A community study of lower urinary tract symptoms in older men in Sydney, Australia. Aust N Z J Surg. May. 2000;70(5):322-8. Not eligible target population. [pmid: 10830592].
2937 Slagle M. Medication update. South Med J. Feb. 2002;95(2):188-91. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11846243].
2938 Sloane PD, Davidson S, Knight N, et al. Severe disruptive vocalizers. J Am Geriatr Soc. Apr. 1999;47(4):439-45. Not eligible target population. [pmid: 10203119].
2939 Slors FJ, van Zuijlen PP, van Dijk GJ. Sexual and bladder dysfunction after total mesorectal excision for benign diseases. Scand J Gastroenterol Suppl. 2000;(232):48-51. Not eligible exposure. [pmid: 11232492].
2940 Sloss EM, Solomon DH, Shekelle PG, et al. Selecting target conditions for quality of care improvement in vulnerable older adults. J Am Geriatr Soc. Apr. 2000;48(4):363-9. Not eligible target population. [pmid: 10798460].
2941 Smith DB, Boileau MA, Buan LD. A self-directed home biofeedback system for women with symptoms of stress, urge, and mixed incontinence. J Wound Ostomy Continence Nurs. Jul. 2000;27(4):240-6. Level of evidence. [pmid: 10896750].
2942 Smith DN, Appell RA, Rackley RR, et al. Collagen injection therapy for post-prostatectomy incontinence. J Urol. Aug. 1998;160(2):364-7. Not eligible target population. [pmid: 9679878].
2943 Smith DS, Krygiel J, Nease RF Jr, et al. Patient preferences for outcomes associated with surgical management of prostate cancer. J Urol. May. 2002;167(5):2117-22. Not eligible target population. [pmid: 11956454].
2944 Smith EA, Woodard JR, Broecker BH, et al. Current urologic management of cloacal exstrophy: experience with 11 patients. J Pediatr Surg. Feb. 1997;32(2):256-61. discussion 61–2. Not eligible target population. [pmid: 9044133].
2945 Smith JP. The problem of incontinence. 1982. J Adv Nurs. Mar. 2006;53(5):493-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16499667].
2946 Smith M. Stress factor. Nurs Stand. Mar 28–Apr 3. 2001;15(28):26. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12216251].
2947 Smith P, Heimer G, Norgren A, et al. Localization of steroid hormone receptors in the pelvic muscles. Eur J Obstet Gynecol Reprod Biol. Jun. 1993;50(1):83-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8365541].
2948 Smith PG, Bradshaw S. Innervation of the proximal urethra of ovariectomized and estrogen-treated female rats. Histol Histopathol. Oct. 2004;19(4):1109-16. Not eligible target population. [pmid: 15375753].
2949 Smith W. Initiative to advise shoppers on continence. Nurs Times. Sep. 13–19. 1995;91(37):11-2. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7567508].
2950 Smoger SH, Felice TL, Kloecker GH. Urinary incontinence among male veterans receiving care in primary care clinics. Annals of Internal Medicine. Apr. 4. 2000;132(7):547-51. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10744591].
2951 Soderberg MW, Johansson B, Masironi B, et al. Pelvic floor sex steroid hormone receptors, distribution and expression in pre- and postmenopausal stress urinary incontinent women. Acta Obstet Gynecol Scand. 2007;86(11):1377-84. Not eligible exposure. [pmid: 17963065].
2952 Sokol ER, Aguilar VC, Sung VW, et al. Combined trans- and periurethral injections of bulking agents for the treatment of intrinsic sphincter deficiency. International Urogynecology Journal. May. 2008;19(5):643-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 21135].
2953 Soler D, Borzyskowski M. Lower urinary tract dysfunction in children with central nervous system tumours. Arch Dis Child. Oct. 1998;79(4):344-7. Not eligible target population. [pmid: 9875046].
2954 Soliman SA, Wadie BS, Ibrahim el HE, et al. Rotoresection versus transurethral resection of the prostate: short-term evaluation of a prospective randomized study. J Urol. Mar. 2007;177(3):1036-9. Not eligible target population. [pmid: 17296407].
2955 Sommer BR, O’Hara R, Askari N, et al. The effect of oxybutynin treatment on cognition in children with diurnal incontinence. J Urol. Jun. 2005;173(6):2125-7. Not eligible target population. [pmid: 15879864].
2956 Sommers BD, Beard CJ, D’Amico AV, et al. Predictors of patient preferences and treatment choices for localized prostate cancer. Cancer. Oct. 15. 2008;113(8):2058-67. Not eligible target population. [pmid: 18704993].
2957 Sonksen J, Ohl DA, Bonde B, et al. Transcutaneous Mechanical Nerve Stimulation (TMNS) using Perineal Vibration--A Novel Method for the Treatment of Female Stress Urinary Incontinence. Paper presented at: 2006 Annual Meeting of the American Urological Association (AUA 2006). Atlanta, Georgia (USA). 20–25 May 2006. Not eligible case series.
2958 Sorbye LW, Finne-Soveri H, Ljunggren G, et al. Urinary incontinence and use of pads--clinical features and need for help in home care at 11 sites in Europe. Scand J Caring Sci. Mar. 2009;23(1):33-44. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18785918].
2959 Sotomayor M, Bernal GF. Transurethral delivery of radiofrequency energy for tissue micro-remodeling in the treatment of stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Dec. 2003;14(6):373-9. Not eligible exposure. [pmid: 14676996].
2960 Sotomayor M, Bernal GF. Twelve-month results of nonsurgical radiofrequency energy micro-remodeling for stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2005;16(3):192-6. discussion 6. Not eligible exposure. [pmid: 15378235].
2961 Soulie M, Cuvillier X, Benaissa A, et al. The tension-free transvaginal tape procedure in the treatment of female urinary stress incontinence: a French prospective multicentre study. Eur Urol. Jun. 2001;39(6):709-14. discussion 15. Not eligible exposure. [pmid: 11464062].
2962 Sousa-Escandon A, Cabrera J, Mantovani F, et al. Adjustable suburethral sling (male remeex system) in the treatment of male stress urinary incontinence: a multicentric European study. Eur Urol. Nov. 2007;52(5):1473-9. Not eligible target population. [pmid: 17560016].
2963 Sousa-Escandon A, Rodriguez Gomez JI, Uribarri Gonzalez C, et al. Externally readjustable sling for treatment of male stress urinary incontinence: points of technique and preliminary results. J Endourol. Feb. 2004;18(1):113-8. Not eligible target population. [pmid: 15006064].
2964 Spaliviero M, Araki M, Culkin DJ, et al. Incidence, management, and prevention of perioperative complications of GreenLight HPS laser photoselective vaporization prostatectomy: experience in the first 70 patients. J Endourol. Mar. 2009;23(3):495-502. Not eligible target population. [pmid: 19265468].
2965 Spaliviero M, Araki M, Wong C. Short-term outcomes of Greenlight HPS laser photoselective vaporization prostatectomy (PVP) for benign prostatic hyperplasia (BPH). J Endourol. Oct. 2008;22(10):2341-7. Not eligible target population. [pmid: 18937595].
2966 Spector WD. Correlates of pressure sores in nursing homes: evidence from the National Medical Expenditure Survey. J Invest Dermatol. Jun. 1994;102(6):42S-5S. Not eligible target popluation. [pmid: 8006435].
2967 Spinelli M, Bertapelle P, Cappellano F, et al. Chronic sacral neuromodulation in patients with lower urinary tract symptoms: results from a national register. J Urol. Aug. 2001;166(2):541-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11458063].
2968 Srinualnad S. Early experience of robotic assisted laparoscopic radical prostatectomy. J Med Assoc Thai. Mar. 2008;91(3):377-82. Not eligible target population. [pmid: 18575292].
2969 Srougi M, Nesrallah LJ, Kauffmann JR, et al. Urinary continence and pathological outcome after bladder neck preservation during radical retropubic prostatectomy: a randomized prospective trial. J Urol. Mar. 2001;165(3):815-8. Not eligible target population. [pmid: 11176476].
2970 Srougi M, Paranhos M, Leite KM, et al. The influence of bladder neck mucosal eversion and early urinary extravasation on patient outcome after radical retropubic prostatectomy: a prospective controlled trial. BJU Int. Apr. 2005;95(6):757-60. Not eligible target population. [pmid: 15794777].
2971 St John W, James H, McKenzie S. “Oh, that’s a bit of a nuisance”: community-dwelling clients ‘ perspectives of urinary continence health service provision. J Wound Ostomy Continence Nurs. Nov. 2002;29(6):312-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12439455].
2972 St John W, Wallis M. Outcome evaluation of a multi-disciplinary community-based continence service for Australian women. Women Health. 2004;40(2):35-52. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15778137].
2973 St John W, Wallis M, James H, et al. Targeting community-dwelling urinary incontinence sufferers: a multi-disciplinary community based model for conservative continence services. Contemp Nurse. Oct. 2004;17(3):211-22. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15551672].
2974 Stach-Lempinen B, Hakala AL, Laippala P, et al. Severe depression determines quality of life in urinary incontinent women. Neurourol Urodyn. 2003;22(6):563-8. Not eligible exposure. [pmid: 12951664].
2975 Stach-Lempinen B, Kirkinen P, Laippala P, et al. Do objective urodynamic or clinical findings determine impact of urinary incontinence or its treatment on quality of life?. Urology. Jan. 2004;63(1):67-71. discussion -2. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14751350].
2976 Stach-Lempinen B, Nygard CH, Laippala P, et al. Is physical activity influenced by urinary incontinence?. BJOG. May. 2004;111(5):475-80. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15104613].
2977 Stanton AL, Bernaards CA, Ganz PA. The BCPT symptom scales: a measure of physical symptoms for women diagnosed with or at risk for breast cancer. J Natl Cancer Inst. Mar. 16. 2005;97(6):448-56. Not eligible target population. [pmid: 15770009].
2978 Starkman JS, Duffy JW 3rd, Wolter CE, et al. The evolution of obstruction induced overactive bladder symptoms following urethrolysis for female bladder outlet obstruction. J Urol. Mar. 2008;179(3):1018-23. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18206925].
2979 Starr CH. Treatment can lead to a long dry spell. Bus Health. Spring. 2002;(Spec No: 15–9):24. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11974567].
2980 Starr CH. Eroding the quality of life. Bus Health. Spring. 2002;4(Spec No: 8–10):23-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11974570].
2981 Starr CH. The numbers lie. Bus Health. Spring. 2002;(Spec No: 4–7):23. Not eligible exposure. [pmid: 11974569].
2982 Staskin DR, Dmochowski RR, Wein AJ. Solifenacin versus tolterodine--a head-to-head study: finally! But not final?. Curr Urol Rep. Nov. 2005;6(6):403-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16238911].
2983 Staskin DR, Rosenberg MT, Dahl NV, et al. Effects of oxybutynin transdermal system on health-related quality of life and safety in men with overactive bladder and prostate conditions. Int J Clin Pract. Jan. 2008;62(1):27-38. Not eligible target population. [pmid: 17983434].
2984 Steele AC, Walsh P, Bentley M, et al. A randomized, double-blind placebo-controlled trial of the effects of the 5-hydroxytriptamine(4) agonist cisapride on the female urinary bladder. Am J Obstet Gynecol. Jul. 2001;185(1):62-4. Not eligible exposure. [pmid: 11483905].
2985 Steers WD, Gray M. A simple method for teaching about voiding disorders. BJU Int. Feb. 2006;97(2):238-42. no primary result. [pmid: 16430620].
2986 Steginga SK, Occhipinti S, Gardiner RA, et al. Making decisions about treatment for localized prostate cancer. BJU Int. Feb. 2002;89(3):255-60. Not eligible target population. [pmid: 11856106].
2987 Stein A, Ratzkovitzki R, Lurie A. Perivesical fat closure during suprapubic prostatectomy: does it prevent urinary leakage? A prospective randomized study. Tech Urol. Summer. 1996;2(2):99-101. Not eligible target population. [pmid: 9118417].
2988 Stein M, Discippio W, Davia M, et al. Biofeedback for the treatment of stress and urge incontinence. J Urol. Mar. 1995;153(3 Pt 1):641-3. Not eligible case series. [pmid: 7861503].
2989 Stein M, Weinberg JJ. Polytetrafluoroethylene vs. polypropylene suture for endoscopic bladder neck suspension. Urology. Aug. 1991;38(2):119-22. Not eligible exposure. [pmid: 1877125].
2990 Steineck G, Helgesen F, Adolfsson J, et al. Quality of life after radical prostatectomy or watchful waiting. N Engl J Med. Sep. 12. 2002;347(11):790-6. Not eligible target population. [pmid: 12226149].
2991 Stenberg A, Heimer G, Holmberg L, et al. Prevalence of postmenopausal symptoms in two age groups of elderly women in relation to oestrogen replacement therapy. Maturitas. Dec. 15. 1999;33(3):229-37. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10656501].
2992 Stenberg A, Heimer G, Ulmsten U, et al. Prevalence of genitourinary and other climacteric symptoms in 61-year-old women. Maturitas. May. 1996;24(1–2):31-6. Not eligible target population. [pmid: 8794431].
2993 Stenzelius K, Mattiasson A, Hallberg IR, et al. Symptoms of urinary and faecal incontinence among men and women 75+ in relations to health complaints and quality of life. Neurourol Urodyn. 2004;23(3):211-22. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15098216].
2994 Stenzelius K, Westergren A, Mattiasson A, et al. Older women and men with urinary symptoms. Arch Gerontol Geriatr. Sep–Oct. 2006;43(2):249-65. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16384617].
2995 Stern JA, Clemens JQ, Tiplitsky SI, et al. Long-term results of the bulbourethral sling procedure. J Urol. May. 2005;173(5):1654-6. Not eligible target population. [pmid: 15821529].
2996 Stewart ST, Lenert L, Bhatnagar V, et al. Utilities for prostate cancer health states in men aged 60 and older. Med Care. Apr. 2005;43(4):347-55. Not eligible target population. [pmid: 15778638].
2997 Stewart WF, Van Rooyen JB, Cundiff GW, et al. Prevalence and burden of overactive bladder in the United States. World J Urol. May. 2003;20(6):327-36. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12811491].
2998 Stikkelbroeck NM, Beerendonk CC, Willemsen WN, et al. The long term outcome of feminizing genital surgery for congenital adrenal hyperplasia: anatomical, functional and cosmetic outcomes, psychosexual development, and satisfaction in adult female patients. J Pediatr Adolesc Gynecol. Oct. 2003;16(5):289-96. Not eligible exposure. [pmid: 14597017].
2999 Stoddart H, Donovan J, Whitley E, et al. Urinary incontinence in older people in the community: a neglected problem?. Br J Gen Pract. Jul. 2001;51(468):548-52. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11462314].
3000 Stoffel JT, Morgan D, Dunn R, et al. Urinary incontinence after stress incontinence surgery: a risk factor for depression. Urology. Jan. 2009;73(1):41-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18952263].
3001 Stone NN, Stock RG. Long-term urinary, sexual, and rectal morbidity in patients treated with iodine-125 prostate brachytherapy followed up for a minimum of 5 years. Urology. Feb. 2007;69(2):338-42. Not eligible target population. [pmid: 17320674].
3002 Stones RW, Padmadas SS, Guo S, et al. Dyspareunia, urinary sensory symptoms, and incontinence among young Chinese women. Arch Sex Behav. Oct. 2006;35(5):561-7. Not eligible exposure. [pmid: 17031583].
3003 Stothers L, Thom D, Calhoun E. Urologic diseases in America project: urinary incontinence in males--demographics and economic burden. J Urol. Apr. 2005;173(4):1302-8. Not eligible target population. [pmid: 15758786].
3004 Strachan-Bennett S. Care homes failing to address continence. Nurs Times. Nov. 8–14. 2005;101(45):6. Not eligible target population. [pmid: 16312070].
3005 Strahle A, Stainton MC. Women’s experience of revealing perinatal bladder function--implications for midwifery care. Women Birth. Mar. 2006;19(1):17-21. guidelines. [pmid: 16792000].
3006 Strasser H, Marksteiner R, Margreiter E, et al. Transurethral ultrasonography-guided injection of adult autologous stem cells versus transurethral endoscopic injection of collagen in treatment of urinary incontinence. World J Urol. Aug. 2007;25(4):385-92. Not eligible exposure. [pmid: 17701044].
3007 Straus SE, Holroyd-Leduc J, Orr MS. Validation of electronic urinary incontinence questionnaires. Can J Urol. Jun. 2010;17(3):5195-9. Not eligible outcomes. [pmid: 20566013].
3008 Stricker PD. Proper patient selection for Contigen Bard Collagen implant. Int J Urol. Apr. 1995;2(Suppl 1):2-6. discussion 16–8. no primary result. [pmid: 7614410].
3009 Strinic T, Bukovic D, Roje D, et al. Epidemiology of pelvic floor disorders between urban and rural female inhabitants. Coll Antropol. Jun. 2007;31(2):483-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17847927].
3010 Stuck AE, Elkuch P, Dapp U, et al. Feasibility and yield of a self-administered questionnaire for health risk appraisal in older people in three European countries. Age Ageing. Nov. 2002;31(6):463-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12446293].
3011 Sturdy D. Dependence and dignity. Nurs Older People. Apr. 2008;20(3):10. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18500125].
3012 Su KC, Mutone MF, Terry CL, et al. Abdominovaginal sacral colpoperineopexy: patient perceptions, anatomical outcomes, and graft erosions. Int Urogynecol J Pelvic Floor Dysfunct. May. 2007;18(5):503-11. Not eligible exposure. [pmid: 16988778].
3013 Su TH, Wang KG, Hsu CY, et al. Prospective comparison of laparoscopic and traditional colposuspensions in the treatment of genuine stress incontinence. Acta Obstet Gynecol Scand. Jul. 1997;76(6):576-82. Not eligible exposure. [pmid: 9246967].
3014 Subak L, Van Den Eeden S, Thom D, et al. Urinary incontinence in women: Direct costs of routine care. Am J Obstet Gynecol. Dec. 2007;197(6):596 e1-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17880904].
3015 Subak LL, Brown JS, Kraus SR, et al. The “costs” of urinary incontinence for women. Obstet Gynecol. Apr. 2006;107(4):908-16. not eligible outcomes. [pmid: 16582131].
3016 Subak LL, Brubaker L, Chai TC, et al. High costs of urinary incontinence among women electing surgery to treat stress incontinence. Obstet Gynecol. Apr. 2008;111(4):899-907. Not eligible exposure. [pmid: 18378749].
3017 Subak LL, Waetjen LE, van den Eeden S, et al. Cost of pelvic organ prolapse surgery in the United States. Obstet Gynecol. Oct. 2001;98(4):646-51. Not eligible exposure. [pmid: 11576582].
3018 Sublett CM. Adding to the evidence base: a review of two qualitative studies. Urol Nurs. Apr. 2008;28(2):130-1. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18488589].
3019 Sueppel C, Kreder K, See W. Improved continence outcomes with preoperative pelvic floor muscle strengthening exercises. Urol Nurs. Jun. 2001;21(3):201-10. Not eligible target population. [pmid: 11998651].
3020 Sullivan LD, Chow VD, Ko DS, et al. An evaluation of quality of life in patients with continent urinary diversions after cystectomy. Br J Urol. May. 1998;81(5):699-704. Not eligible exposure. [pmid: 9634044].
3021 Sumino Y, Hirata Y, Sato F, et al. Growth mechanism of satellite cells in human urethral rhabdosphincter. Neurourol Urodyn. 2007;26(4):552-61. Not eligible target population. [pmid: 17262837].
3022 Sumiya T, Kawamura K, Tokuhiro A, et al. A survey of wheelchair use by paraplegic individuals in Japan. Part 2: Prevalence of pressure sores. Spinal Cord. Sep. 1997;35(9):595-8. Not eligible target population. [pmid: 9300965].
3023 Sun MJ, Chang NE, Chen GD, et al. Comparison of suprapubic versus transobturator surgical treatments of female stress urinary incontinence. Taiwan J Obstet Gynecol. Jun. 2008;47(2):175-9. Not eligible exposure. [pmid: 18603502].
3024 Sun MJ, Chang SY, Lin KC, et al. Is an indwelling catheter necessary for bladder drainage after modified Burch colposuspension?. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2004;15(3):203-7. Not eligible exposure. [pmid: 15168002].
3025 Sun MJ, Ng SC, Tsui KP, et al. Are there any predictors for failed Burch colposuspension?. Taiwan J Obstet Gynecol. Mar. 2006;45(1):33-8. Not eligible exposure. [pmid: 17272205].
3026 Sung VW, Glasgow MA, Wohlrab KJ, et al. Impact of age on preoperative and postoperative urinary incontinence quality of life. Am J Obstet Gynecol. Dec. 2007;197(6):680 e1-5. Not eligible target population. [pmid: 18060981].
3027 Sung VW, Kauffman N, Raker CA, et al. Validation of decision-making outcomes for female pelvic floor disorders. Am J Obstet Gynecol. May. 2008;198(5):575 e1-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18313632].
3028 Sung VW, West DS, Hernandez AL, et al. Association between urinary incontinence and depressive symptoms in overweight and obese women. Am J Obstet Gynecol. May. 2009;200(5):557 e1-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 19236869].
3029 Sureshkumar P, Cumming RG, Craig JC. Validity and reliability of parental report of frequency, severity and risk factors of urinary tract infection and urinary incontinence in children. J Urol. Jun. 2006;175(6):2254-62. Not eligible target population. [pmid: 16697849].
3030 Susset J, Galea G, Manbeck K, et al. A predictive score index for the outcome of associated biofeedback and vaginal electrical stimulation in the treatment of female incontinence. J Urol. May. 1995;153(5):1461-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7714966].
3031 Suzuki T, Yasuda K, Yamanishi T, et al. Randomized, double-blind, sham-controlled evaluation of the effect of functional continuous magnetic stimulation in patients with urgency incontinence. Neurourol Urodyn. 2007;26(6):767-72. Not eligible target population. [pmid: 17397061].
3032 Sveen U, Thommessen B, Bautz-Holter E, et al. Well-being and instrumental activities of daily living after stroke. Clin Rehabil. May. 2004;18(3):267-74. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15137558].
3033 Swaddiwudhipong W, Koonchote S, Nguntra P, et al. Assessment of socio-economic, functional and medical problems among the elderly in one rural community of Thailand. Southeast Asian J Trop Med Public Health. Sep. 1991;22(3):299-306. Not eligible target population. [pmid: 1818379].
3034 Swaffield J. The management and development of continence services within the framework of the NHS and Community Care Act 1990. J Clin Nurs. Mar. 1994;3(2):119-24. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8156134].
3035 Swanson JG, Skelly J, Hutchison B, et al. Urinary incontinence in Canada. National survey of family physicians’ knowledge, attitudes, and practices. Can Fam Physician. Jan. 2002;48:86-92. not eligible outcomes. [pmid: 11852616].
3036 Swarztrauber K, Graf E, Cheng E. The quality of care delivered to Parkinson’s disease patients in the U.S. Pacific Northwest Veterans Health System. BMC Neurol. 2006;6:26. Not eligible target population. [pmid: 16875503].
3037 Swierzewski SJ 3rd, Gormley EA, Belville WD, et al. The effect of terazosin on bladder function in the spinal cord injured patient. J Urol. Apr. 1994;151(4):951-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7907374].
3038 Swift SE. The reliability of performing a screening cystometrogram using a fetal monitoring device for the detection of detrusor instability. Obstet Gynecol. May. 1997;89(5 Pt 1):708-12. Not eligible exposure. [pmid: 9166306].
3039 Swithinbank L, Abrams P. Lower urinary tract symptoms in community-dwelling women: defining diurnal and nocturnal frequency and ‘the incontinence case’. BJU Int. Sep. 2001;88(Suppl 2):18-22. discussion 49–50. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11589665].
3040 Sykes D, Castro R, Pons ME, et al. Characteristics of female outpatients with urinary incontinence participating in a 6-month observational study in 14 European countries. Maturitas. Nov. 30. 2005;52(Suppl 2):S13-23. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16297580].
3041 Symon Z, Daignault S, Symon R, et al. Measuring patients’ expectations regarding health-related quality-of-life outcomes associated with prostate cancer surgery or radiotherapy. Urology. Dec. 2006;68(6):1224-9. Not eligible target population. [pmid: 17141840].
3042 Szonyi G, Millard RJ. Controlled trial evaluation of a General Practitioner education package on incontinence: use of a mailed questionnaire. Br J Urol. Jun. 1994;73(6):615-20. Not eligible target population. [pmid: 8032826].
3043 Tadros Y, Ruiz-Deya G, Crawford BE, et al. In vivo proteomic analysis of cytokine expression in laser capture-microdissected urothelial cells of obstructed ureteropelvic junction procured by laparoscopic dismembered pyeloplasty. J Endourol. Jun. 2003;17(5):333-6. Not eligible target population. [pmid: 12885361].
3044 Tahseen S, Reid P. Effect of transobturator tape on overactive bladder symptoms and urge urinary incontinence in women with mixed urinary incontinence. Obstet Gynecol. Mar. 2009;113(3):617-23. Not eligible target population. [pmid: 19300325].
3045 Tahseen S, Reid PC, Charan P. Short-term complications of the trans-obturator foramen procedure for urinary stress incontinence. J Obstet Gynaecol. Jul. 2007;27(5):500-2. Not eligible exposure. [pmid: 17701800].
3046 Takahashi S, Tajima A, Matsushima H, et al. Clinical efficacy of an alpha1A/D-adrenoceptor blocker (naftopidil) on overactive bladder symptoms in patients with benign prostatic hyperplasia. Int J Urol. Jan. 2006;13(1):15-20. Not eligible target population. [pmid: 16448426].
3047 Takayanagi R, Mizushima H, Ozeki T, et al. Analysis of pharmacological effects of drugs used for treatment of urinary disturbance based on anticholinergic and smooth muscle-relaxing effects. Biol Pharm Bull. Jul. 2007;30(7):1297-300. Not eligible target population. [pmid: 17603170].
3048 Takazawa K, Arisawa K. Relationship between the type of urinary incontinence and falls among frail elderly women in Japan. J Med Invest. Aug. 2005;52(3–4):165-71. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16167534].
3049 Talbot LA, Cox M. Differences in coping strategies among community-residing older adults with functional urinary continence, dysfunctional urinary continence and actual urinary incontinence. Ostomy Wound Manage. Nov–Dec. 1995;41(10):30-2. 4. 7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8679048].
3050 Talcott JA, Clark JA, Manola J, et al. Bringing prostate cancer quality of life research back to the bedside: translating numbers into a format that patients can understand. J Urol. Oct. 2006;176(4 Pt 1):1558-63. discussion 63–4. Not eligible target population. [pmid: 16952681].
3051 Talcott JA, Manola J, Clark JA, et al. Time course and predictors of symptoms after primary prostate cancer therapy. J Clin Oncol. Nov. 1. 2003;21(21):3979-86. Not eligible target population. [pmid: 14581420].
3052 Talcott JA, Rieker P, Clark JA, et al. Patient-reported symptoms after primary therapy for early prostate cancer: results of a prospective cohort study. J Clin Oncol. Jan. 1998;16(1):275-83. Not eligible target population. [pmid: 9440753].
3053 Tamanini JT, Almeida FG, Girotti ME, et al. The Portuguese validation of the International Consultation on Incontinence Questionnaire-Vaginal Symptoms (ICIQ-VS) for Brazilian women with pelvic organ prolapse. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2008;19(10):1385-91. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18506383].
3054 Tamanini JT, Dambros M, D’Ancona CA, et al. Concurrent validity, internal consistency and responsiveness of the Portuguese version of the King’s Health Questionnaire (KHQ) in women after stress urinary incontinence surgery. Int Braz J Urol. Nov–Dec. 2004;30(6):479-86. Not eligible exposure. [pmid: 15663805].
3055 Tamanini JT, D’Ancona CA, Netto NR Jr. Treatment of intrinsic sphincter deficiency using the Macroplastique Implantation System: two-year follow-up. J Endourol. Nov. 2004;18(9):906-11. Not eligible exposure. [pmid: 15659931].
3056 Tamanini JT, D’Ancona CA, Netto NR. Macroplastique implantation system for female stress urinary incontinence: long-term follow-up. J Endourol. Dec. 2006;20(12):1082-6. Not eligible exposure. [pmid: 17206907].
3057 Tamanini JT, D’Ancona CA, Tadini V, et al. Macroplastique implantation system for the treatment of female stress urinary incontinence. J Urol. Jun. 2003;169(6):2229-33. Not eligible exposure. [pmid: 12771756].
3058 Tan AH, Gilling PJ, Kennett KM, et al. Long-term results of high-power holmium laser vaporization (ablation) of the prostate. BJU Int. Nov. 2003;92(7):707-9. Not eligible target population. [pmid: 14616451].
3059 Tan TL, Bergmann MA, Griffiths D, et al. Which stop test is best? Measuring detrusor contractility in older females. J Urol. Mar. 2003;169(3):1023-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12576837].
3060 Tanji H, Anderson KE, Gruber-Baldini AL, et al. Mutuality of the marital relationship in Parkinson’s disease. Mov Disord. Oct. 15. 2008;23(13):1843-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18759355].
3061 Tannenbaum C, Bachand G, Dubeau CE, et al. Experience of an incontinence clinic for older women: no apparent age limit for potential physical and psychological benefits. J Womens Health Gend Based Med. Oct. 2001;10(8):751-6. no associative hypothesis tested. [pmid: 11703887].
3062 Tannenbaum C, Brouillette J, Corcos J. Rating improvements in urinary incontinence: do patients and their physicians agree?. Age Ageing. Jul. 2008;37(4):379-83. Not eligible exposure. [pmid: 18586834].
3063 Tannenbaum C, Brouillette J, Korner-Bitensky N, et al. Creation and testing of the Geriatric Self-Efficacy Index for Urinary Incontinence. J Am Geriatr Soc. Mar. 2008;56(3):542-7. Not eligible outcomes. [pmid: 18179504].
3064 Tannenbaum C, Labrecque D, Lepage C. Understanding barriers to continence care in institutions. Canadian Journal on Aging. 2005;24(2):151-9. Not eligible target population. [pmid: 16082618].
3065 Tannenbaum C, Mayo N. Women’s health priorities and perceptions of care: a survey to identify opportunities for improving preventative health care delivery for older women. Age Ageing. Nov. 2003;32(6):626-35. Not eligble exposure. [pmid: 14600004].
3066 Tannenbaum C, Mayo N, Ducharme F. Older women’s health priorities and perceptions of care delivery: results of the WOW health survey. CMAJ. Jul. 19. 2005;173(2):153-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16027431].
3067 Taunton RL, Swagerty DL, Lasseter JA, et al. Continent or incontinent? That is the question. J Gerontol Nurs. Sep. 2005;31(9):36-44. Not eligible target population. [pmid: 16190011].
3068 Tayal SC, Bansal SK, Chadha DK. Hypopituitarism: a difficult diagnosis in elderly people but worth a search. Age Ageing. Jul. 1994;23(4):320-2. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7976781].
3069 Taylor PH, Sussman DO. Contemporary treatment options for overactive bladder. JAAPA. Nov. 2005;(Suppl):3-13. quiz 4–5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16315503].
3070 Tcherniakovsky M, Fernandes CE, Bezerra CA, et al. Comparative results of two techniques to treat stress urinary incontinence: synthetic transobturator and aponeurotic slings. Int Urogynecol J Pelvic Floor Dysfunct. Aug. 2009;20(8):961-6. Not eligible exposure. [pmid: 19582386].
3071 Te AE, Malloy TR, Stein BS, et al. Impact of prostate-specific antigen level and prostate volume as predictors of efficacy in photoselective vaporization prostatectomy: analysis and results of an ongoing prospective multicentre study at 3 years. BJU Int. Jun. 2006;97(6):1229-33. Not eligible target population. [pmid: 16686717].
3072 Tediosi F, Parazzini F, Bortolotti A, et al. The cost of urinary incontinence in Italian women. A cross-sectional study. Gruppo di Studio Incontinenza. Pharmacoeconomics. Jan. 2000;17(1):71-6. no associative hypothesis tested. [pmid: 10747766].
3073 Tefilli MV, Gheiler EL, Tiguert R, et al. Quality of life in patients undergoing salvage procedures for locally recurrent prostate cancer. J Surg Oncol. Nov. 1998;69(3):156-61. Not eligible target population. [pmid: 9846502].
3074 Tei TM, Stolzenburg T, Buntzen S, et al. Use of transpelvic rectus abdominis musculocutaneous flap for anal cancer salvage surgery. Br J Surg. May. 2003;90(5):575-80. Not eligible target population. [pmid: 12734865].
3075 Teichman JM. Laparoscopic Burch colposuspension. Tech Urol. Spring. 1995;1(1):19-24. Not eligible exposure. [pmid: 9118362].
3076 Teichman JM, Harris JM, Currie DM, et al. Malone antegrade continence enema for adults with neurogenic bowel disease. J Urol. Oct. 1998;160(4):1278-81. Not eligible target population. [pmid: 9751335].
3077 Teleman P, Lidfeldt J, Nerbrand C, et al. Lower urinary tract symptoms in middle-aged women--prevalence and attitude towards mild urinary incontinence: a community-based population study. Acta Obstet Gynecol Scand. Nov. 2005;84(11):1108-12. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16232181].
3078 Tellez-Zenteno JF, Matijevic S, Wiebe S. Somatic comorbidity of epilepsy in the general population in Canada. Epilepsia. Dec. 2005;46(12):1955-62. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16393162].
3079 Temml C, Haidinger G, Schmidbauer J, et al. Urinary incontinence in both sexes: prevalence rates and impact on quality of life and sexual life. Neurourol Urodyn. 2000;19(3):259-71. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10797583].
3080 Temml C, Heidler S, Ponholzer A, et al. Prevalence of the overactive bladder syndrome by applying the International Continence Society definition. Eur Urol. Oct. 2005;48(4):622-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15964133].
3081 Tennstedt S. Design of the Stress Incontinence Surgical Treatment Efficacy Trial (SISTEr). Urology. Dec. 2005;66(6):1213-7. Not eligible exposure. [pmid: 16360445].
3082 Tennstedt SL, Fitzgerald MP, Nager CW, et al. Quality of life in women with stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. May. 2007;18(5):543-9. Not eligible exposure. [pmid: 17036169].
3083 Tennstedt SL, Litman HJ, Zimmern P, et al. Quality of life after surgery for stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Dec. 2008;19(12):1631-8. Not eligible exposure. [pmid: 18682875].
3084 Teplin V, Vittinghoff E, Lin F, et al. Oophorectomy in premenopausal women: health-related quality of life and sexual functioning. Obstet Gynecol. Feb. 2007;109(2 Pt 1):347-54. Not eligible target population. [pmid: 17267835].
3085 ter Meulen PH, Zambon V, Kessels AG, et al. Quality of life, functional outcome and durability of the AMS 800 artificial urinary sphincter in patients with intrinsic sphincter deficiency. Urol Int. 2003;71(1):55-60. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12845262].
3086 Ternent L, Vale L, Buckley B, et al. Measuring outcomes of importance to women with stress urinary incontinence. BJOG. Apr. 2009;116(5):719-25. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 19298440].
3087 Tester K. Continence. Changing time. Nurs Times. Apr. 3–9. 1991;87(14):70. Comment. [pmid: 2011567].
3088 Teunissen D, Lagro-Janssen T. Urinary incontinence in community dwelling elderly: are there sex differences in help-seeking behaviour?. Scand J Prim Health Care. Dec. 2004;22(4):209-16. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15765635].
3089 Teunissen D, Van Den Bosch W, Van Weel C, et al. “It can always happen”: the impact of urinary incontinence on elderly men and women. Scand J Prim Health Care. Sep. 2006;24(3):166-73. no associated hypothesis tested. [pmid: 16923626].
3090 Teunissen D, van Weel C, Lagro-Janssen T. Urinary incontinence in older people living in the community: examining help-seeking behaviour. Br J Gen Pract. Oct. 2005;55(519):776-82. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16212853].
3091 Tewari A, Jhaveri J, Rao S, et al. Total reconstruction of the vesico-urethral junction. BJU Int. Apr. 2008;101(7):871-7. Not eligible target population. [pmid: 18321319].
3092 Tewari A, Srivasatava A, Menon M. A prospective comparison of radical retropubic and robot-assisted prostatectomy: experience in one institution. BJU Int. Aug. 2003;92(3):205-10. Not eligible target population. [pmid: 12887468].
3093 Tewari AK, Bigelow K, Rao S, et al. Anatomic restoration technique of continence mechanism and preservation of puboprostatic collar: a novel modification to achieve early urinary continence in men undergoing robotic prostatectomy. Urology. Apr. 2007;69(4):726-31. Not eligible target population. [pmid: 17445659].
3094 Thakar R, Stanton S, Prodigalidad L, et al. Secondary colposuspension: results of a prospective study from a tertiary referral centre. BJOG. Oct. 2002;109(10):1115-20. Not eligible exposure. [pmid: 12387463].
3095 Theodorou C, Floratos D, Katsifotis C, et al. Transvaginal incisionless bladder neck suspension. A simplified technique for female genuine stress incontinence. Int Urol Nephrol. 1998;30(3):273-8. Not eligible exposure. [pmid: 9696332].
3096 Theodorou C, Moutzouris G, Floratos D, et al. Incontinence after surgery for benign prostatic hypertrophy: the case for complex approach and treatment. Eur Urol. 1998;33(4):370-5. Not eligible target population. [pmid: 9612679].
3097 Theofrastous JP, Bump RC, Elser DM, et al. Correlation of urodynamic measures of urethral resistance with clinical measures of incontinence severity in women with pure genuine stress incontinence. The Continence Program for Women Research Group. Am J Obstet Gynecol. Aug. 1995;173(2):407-12. discussion 12–4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7645615].
3098 Thom DH, Nygaard IE, Calhoun EA. Urologic diseases in America project: urinary incontinence in women-national trends in hospitalizations, office visits, treatment and economic impact. J Urol. Apr. 2005;173(4):1295-301. Not eligible outcomes. [pmid: 15758785].
3099 Thom DH, van den Eeden SK, Brown JS. Evaluation of parturition and other reproductive variables as risk factors for urinary incontinence in later life. Obstet Gynecol. Dec. 1997;90(6):983-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9397116].
3100 Thom DH, van den Eeden SK, Ragins AI, et al. Differences in prevalence of urinary incontinence by race/ethnicity. J Urol. Jan. 2006;175(1):259-64. Not eligible target population. [pmid: 16406923].
3101 Thomas KK, Sampselle C, Gray M, et al. Getting into nursing research: dropping in on AWHONN’s Continence for Women researchers. AWHONN Lifelines. Feb–Mar. 1999;3(1):24-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10362916].
3102 Thomas P, Ingrand P, Lalloue F, et al. Reasons of informal caregivers for institutionalizing dementia patients previously living at home: the Pixel study. Int J Geriatr Psychiatry. Feb. 2004;19(2):127-35. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14758578].
3103 Thomas S. Investing in continence. Nurs Stand. Sep. 15–21. 1999;13(52):38. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10693510].
3104 Thomas S. Commissioning continence services--turning policy into action. Nurs Times. May. 18. 2004;100(20):52-5. 7. 8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15176280].
3105 Thompson IM Jr, Tangen CM, Paradelo J, et al. Adjuvant radiotherapy for pathologically advanced prostate cancer: a randomized clinical trial. JAMA. Nov. 15. 2006;296(19):2329-35. Not eligible target population. [pmid: 17105795].
3106 Thompson J, Crawford M. Patients contribute to continence care. Prof Nurse. Feb. 2001;16(5 Suppl):S6-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12029741].
3107 Thompson PK, Duff DS, Thayer PS. Stress incontinence in women under 50: does urodynamics improve surgical outcome?. Int Urogynecol J Pelvic Floor Dysfunct. 2000;11(5):285-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11052563].
3108 Thompson RH, Slezak JM, Webster WS, et al. Radical prostatectomy for octogenarians: how old is too old?. Urology. Nov. 2006;68(5):1042-5. Not eligible target population. [pmid: 17095073].
3109 Thomson AJ, Tincello DG. The influence of pad test loss on management of women with urodynamic stress incontinence. BJOG. Aug. 2003;110(8):771-3. Not eligible target population. [pmid: 12892690].
3110 Thongboonkerd V, McLeish KR, Arthur JM, et al. Proteomic analysis of normal human urinary proteins isolated by acetone precipitation or ultracentrifugation. Kidney Int. Oct. 2002;62(4):1461-9. Not eligible target population. [pmid: 12234320].
3111 Thornton MJ, Lam A, King DW. Bowel, bladder and sexual function in women undergoing laparoscopic posterior compartment repair in the presence of apical or anterior compartment dysfunction. Aust N Z J Obstet Gynaecol. Jun. 2005;45(3):195-200. Not eligible exposure. [pmid: 15904443].
3112 Thorpe AC. How do we raise awareness and ensure the correct diagnosis and management of female urinary incontinence?. BJU Int. Jun. 2006;97(6):1141-3. no primary result. [pmid: 16686698].
3113 Thurman AR, Litts PL, O’Rourke K, et al. Patient acceptance of medical student participation in an outpatient obstetric/gynecologic clinic. J Reprod Med. Feb. 2006;51(2):109-14. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16572911].
3114 Thuroff S, Chaussy C. High-intensity focused ultrasound: complications and adverse events. Mol Urol. Fall. 2000;4(3):183-7. discussion 9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11062373].
3115 Tibaek S, Gard G, Klarskov P, et al. Prevalence of lower urinary tract symptoms (LUTS) in stroke patients: a cross-sectional, clinical survey. Neurourol Urodyn. 2008;27(8):763-71. Not eligible exposure. [pmid: 18551565].
3116 Tibaek S, Klarskov P, Lund Hansen B, et al. Pelvic floor muscle training before transurethral resection of the prostate: a randomized, controlled, blinded study. Scand J Urol Nephrol. 2007;41(4):329-34. Not eligible target population. [pmid: 17763226].
3117 Tikkinen KA, Auvinen A, Tiitinen A, et al. Reproductive factors associated with nocturia and urinary urgency in women: a population-based study in Finland. Am J Obstet Gynecol. Aug. 2008;199(2):153 e1-12. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18486094].
3118 Tincello DG, Alfirevic Z. Important clinical outcomes in urogynecology: views of patients, nurses and medical staff. Int Urogynecol J Pelvic Floor Dysfunct. 2002;13(2):96-8. discussion 8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12054189].
3119 Tincello DG, Bolderson J, Richmond DH. Preliminary experience with a urinary control device in the management of women with genuine stress incontinence. Br J Urol. Nov. 1997;80(5):752-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9393297].
3120 Tincello DG, Williams KS, Joshi M, et al. Urinary diaries: a comparison of data collected for three days versus seven days. Obstet Gynecol. Feb. 2007;109(2 Pt 1):277-80. Not eligible outcomes. [pmid: 17267824].
3121 Tinnion E, Jowitt F. The active urine collection device: a novel continence management system focusing particularly on the needs of disabled women. Disabil Rehabil. Nov. 10. 2000;22(16):745-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11117595].
3122 Tinnion E, Jowitt F, Clarke-O’Neill S, et al. The further development of the active urine collection device: a novel continence management system. Proc Inst Mech Eng [H]. 2003;217(4):291-6. No associative hypothesis tested. [pmid: 12885199].
3123 Tomalik-Scharte D, Jetter A, Kinzig-Schippers M, et al. Effect of propiverine on cytochrome P450 enzymes: a cocktail interaction study in healthy volunteers. Drug Metab Dispos. Dec. 2005;33(12):1859-66. Not eligible target population. [pmid: 16183781].
3124 Tomlinson AJ, Thornton JG. A randomised controlled trial of antibiotic prophylaxis for vesico-vaginal fistula repair. Br J Obstet Gynaecol. Apr. 1998;105(4):397-9. Not eligible exposure. [pmid: 9609264].
3125 Tomlinson G, Detsky AS. Composite End Points in Randomized Trials: There Is No Free Lunch. JAMA. January. 20. 2010. 2010;303(3):267-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 20085955].
3126 Tomoe H, Kondo A, Takei M, et al. Quality of life assessments in women operated on by tension-free vaginal tape (TVT). Int Urogynecol J Pelvic Floor Dysfunct. Mar–Apr. 2005;16(2):114-8. discussion 08. Not eligible exposure. [pmid: 15448883].
3127 Tomoe H, Sekiguchi Y, Horiguchi M, et al. Questionnaire survey on female urinary frequency and incontinence. Int J Urol. Jul. 2005;12(7):621-30. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16045554].
3128 Tong Y, Jia Q, Sun Y, et al. Acupuncture in the treatment of diabetic bladder dysfunction. J Altern Complement Med. Aug. 2009;15(8):905-9. Not eligible target population. [pmid: 19678782].
3129 Torres C, Ciocon JO, Galindo D, et al. Clinical approach to urinary incontinence: a comparison between internists and geriatricians. Int Urol Nephrol. 2001;33(3):549-52. no associative hypothesis tested. [pmid: 12230293].
3130 Townsend JC, Sadler WA, Shanks GM. The effect of storage pH on the precipitation of proteins in deep frozen urine samples. Ann Clin Biochem. Jan. 1987;24(Pt 1):111-2. Not eligible target population. [pmid: 3827174].
3131 Townsend MK, Curhan GC, Resnick NM, et al. Postmenopausal hormone therapy and incident urinary incontinence in middle-aged women. Am J Obstet Gynecol. Jan. 2009;200(1):86 e1-5. Not eligible exposure. [pmid: 19019333].
3132 Trabuco EC, Klingele CJ, Weaver AL, et al. Medium-term comparison of continence rates after rectus fascia or midurethral sling placement. American Journal of Obstetrics & Gynecology. Mar. 2009;200(3):300.e1-e6. Not eligible exposure. [pmid: 19167695].
3133 Trieman N, Hughes J, Leff J. The TAPS Project 42: the last to leave hospital--a profile of residual long-stay populations and plans for their resettlement. Team for the Assessment of Psychiatric Services. Acta Psychiatr Scand. Nov. 1998;98(5):354-9. Not eligible target population. [pmid: 9845172].
3134 Trigo Rocha F, Gomes C, Figueiredo J, et al. Adjustable Transobturator Sling (Argus TRG) for the Treatment of Post Radical Prostatectomy Urinary Incontinence (Prpui). Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep –3 Oct 2009. Not eligible target population.
3135 Trigo Rocha F, Gomes CM, Mitre AI, et al. A prospective study evaluating the efficacy of the artificial sphincter AMS 800 for the treatment of postradical prostatectomy urinary incontinence and the correlation between preoperative urodynamic and surgical outcomes. Urology. Jan. 2008;71(1):85-9. Not eligible target population. [pmid: 18242371].
3136 Trigo-Rocha F, Gomes CM, Pompeo AC, et al. Prospective study evaluating efficacy and safety of Adjustable Continence Therapy (ProACT) for post radical prostatectomy urinary incontinence. Urology. May. 2006;67(5):965-9. Not eligible target population. [pmid: 16698356].
3137 Tsai E, Yang C, Chen H, et al. Bladder neck circulation by Doppler ultrasonography in postmenopausal women with urinary stress incontinence. Obstet Gynecol. Jul. 2001;98(1):52-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11430956].
3138 Tseng IJ, Chen YT, Chen MT, et al. Prevalence of urinary incontinence and intention to seek treatment in the elderly. J Formos Med Assoc. Oct. 2000;99(10):753-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11061069].
3139 Tseng LH, Wang AC, Lin YH, et al. Randomized comparison of the suprapubic arc sling procedure vs tension-free vaginal taping for stress incontinent women. Int Urogynecol J Pelvic Floor Dysfunct. May–Jun. 2005;16(3):230-5. Not eligible exposure. [pmid: 15875240].
3140 Tsui KP, Ng SC, Yeh GP, et al. Outcomes of autologous fascial slingplasty procedure for treating female urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Jul. 2008;19(7):949-54. Not eligible exposure. [pmid: 18231696].
3141 Tubaro A, Zattoni F, Prezioso D, et al. Italian validation of the International Consultation on Incontinence Questionnaires. BJU Int. Jan. 2006;97(1):101-8. no associated hypothesis tested. [pmid: 16336337].
3142 Turkan A, Inci Y, Fazli D. The short-term effects of physical therapy in different intensities of urodynamic stress incontinence. Gynecol Obstet Invest. 2005;59(1):43-8. Case-series. [pmid: 15459518].
3143 Turnbull GB. An ostomy can mean continence. Ostomy Wound Manage. Dec. 2004;50(12):24-6. Not eligible target population. [pmid: 15632452].
3144 Turner CE, Young JM, Solomon MJ, et al. Vaginal delivery compared with elective caesarean section: the views of pregnant women and clinicians. BJOG. Nov. 2008;115(12):1494-502. Not eligible exposure. [pmid: 18752584].
3145 Turner D. The costs of stress urinary incontinence. Health Serv J. Sep. 16. 2004;114(5923). suppl 11–4. following 54. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15503909].
3146 Twiss CO, Fischer MC, Nitti VW. Comparison between reduction in 24-hour pad weight, International Consultation on Incontinence-Short Form (ICIQ-SF) score, International Prostate Symptom Score (IPSS), and Post-Operative Patient Global Impression of Improvement (PGI-I) score in patient evaluation after male perineal sling. Neurourol Urodyn. 2007;26(1):8-13. Not eligible target population. [pmid: 17016797].
3147 U.S. Food and Drug Administration CfDEaR. A Randomized, Double-Blind, Placebo-Controlled, Parallel Group, Multicenter Safety and Efficacy, Phase 4 Study of VESIcare® (Solifenacin Succinate) or Placebo in Combination With Tamsulosin HCl for the Treatment of Residual OAB Symptoms of Urgency and Frequency in Men VICTOR: VESIcare® In Combination With Tamsulosin in OAB Residual Symptoms. Available at: http://www.clinicalstudyresults.org/drugdetails/?drug_name_id=836&sort=c.company_name&page=1&drug_id=4521. Accessed June 25, 2010. Not eligible target population.
3148 U.S. Food and Drug Administration CfDEaR. Medical Review for ANAFRANIL (Brand Name Drug). Available at: http://www.accessdata.fda.gov/drugsatfda_docs/nda/99/019906_S022_ANAFRANIL_AP.pdf. Accessed June 25, 2010. Not eligible exposure.
3149 U.S. Food and Drug Administration CfDEaR. Statistical Review for Botulinum Toxin Type B Product Approval Information. Available at: internal-pdf://ucm094414-0321775616/ucm094414.pdf. Accessed June 25, 2010. Not eligible treatment.
3150 U.S. Food and Drug Administration CfDEaR. Product Monograph for BOTOX COSMETIC. Available at: http://webprod.hc-sc.gc.ca/dpd-bdpp/info.do?lang=eng&code=67653. Accessed June 25, 2010. Not eligible treatment.
3151 U.S. Food and Drug Administration CfDEaR. Medical Review for PAMELOR (Brand Name Drug). Available at: http://www.accessdata.fda.gov/drugsatfda_docs/nda/2001/018013_s053_PAMELOR%20CAPSULES.pdf. Accessed June 25, 2010. Not eligible exposure.
3152 U.S. Food and Drug Administration CfDEaR. Statistical Review for Botulinum Toxin Type A. Available at: http://www.fda.gov/downloads/Drugs/DevelopmentApprovalProcess/HowDrugsareDevelopedandApproved/ApprovalApplications/TherapeuticBiologicApplications/ucm088547.pdf. Accessed June 25, 2010. Not eligible treatment.
3153 U.S. Food and Drug Administration CfDEaR. Medical Review for Ditropan Tablets/Syrup B. Available at: http://www.accessdata.fda.gov/drugsatfda_docs/nda/2003/018211_s014&s016_DITROPAN%20TABLETS.pdf. Accessed June 25, 2010. Not eligible treatment.
3154 U.S. Food and Drug Administration CfDEaR. Medical Review for Ditropan Tablets/Syrup. Available at: http://www.accessdata.fda.gov/drugsatfda_docs/nda/2003/017577_s032&s033_DITROPAN%20TABS.pdf. Accessed June 25, 2010. Not eligible treatment.
3155 U.S. Food and Drug Administration CfDEaR. Statistical Review for Premarin (Conjugated Estrogens) Tablets. Available at: http://www.accessdata.fda.gov/drugsatfda_docs/nda/2003/21-417_Premarin.cfm. Accessed June 25, 2010. Not eligible exposure.
3156 U.S. Food and Drug Administration CfDEaR. Statistical Review for VesiCare (Solifenacin Succinate) Tablets. Available at: http://www.accessdata.fda.gov/drugsatfda_docs/nda/2004/21-518_VesiCare.cfm. Accessed June 25, 2010. Published data.
3157 U.S. Food and Drug Administration CfDEaR. Statistical Review for Sanctura (Trospium Chloride) Tablets. Available at: http://www.accessdata.fda.gov/drugsatfda_docs/nda/2004/21-595_Sanctura.cfm. Accessed June 25, 2010. Published data.
3158 U.S. Food and Drug Administration CfDEaR. Medical Review for Synthetic Conjugated Estrogens, A vaginal cream, 0.625 mg/g. Available at: http://www.accessdata.fda.gov/drugsatfda_docs/nda/2008/021788_synthetic_conjugated_estrogens_toc.cfm. Accessed June 25, 2010. Not eligible treatment.
3159 U.S. Food and Drug Administration CfDEaR. Statistical Review for Dysport (abobotulinumtoxinA) Injection. Available at: http://www.accessdata.fda.gov/drugsatfda_docs/nda/2009/125274s000TOC.cfm. Accessed June 25, 2010. Not eligible target population.
3160 Uchil D, Thakar R, Sultan AH, et al. Continence pads: have we got it right?. Int Urogynecol J Pelvic Floor Dysfunct. May. 2006;17(3):234-8. Not eligible exposure. [pmid: 15999216].
3161 Uckert S, Stief CG, Odenthal KP, et al. Responses of isolated normal human detrusor muscle to various spasmolytic drugs commonly used in the treatment of the overactive bladder. Arzneimittelforschung. May. 2000;50(5):456-60. Not eligible target population. [pmid: 10858873].
3162 Ukoli FA, Lynch BS, Adams-Campbell LL. Radical prostatectomy and quality of life among African Americans. Ethn Dis. Autumn. 2006;16(4):988-93. Not eligible target population. [pmid: 17061757].
3163 Ullrich NF, Comiter CV. The male sling for stress urinary incontinence: 24-month followup with questionnaire based assessment. J Urol. Jul. 2004;172(1):207-9. Not eligible target population. [pmid: 15201775].
3164 Ulmsten U, Henriksson L, Johnson P, et al. An ambulatory surgical procedure under local anesthesia for treatment of female urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1996;7(2):81-5. discussion 5–6. Not eligible exposure. [pmid: 8798092].
3165 Umlauf MG, Mathis JA. Urinary incontinence among primiparous women. Urol Nurs. Dec. 1995;15(4):112-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8701327].
3166 Umlauf MG, Sherman SM. Symptoms of urinary incontinence among older community-dwelling men. J Wound Ostomy Continence Nurs. Nov. 1996;23(6):314-21. Not eligible target population. [pmid: 9043282].
3167 Unsworth J. Continence. Strategic renewal. Nurs Times. Apr. 19–25. 1995;91(16):60-2. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7731863].
3168 Upton N, Reed V. The meaning of incontinence in dementia care. Int J Psychiatr Nurs Res. Sep. 2005;11(1):1200-10. Not eligible target population. [pmid: 16268229].
3169 Urinary Incontinence, Treatment N. Design of the Behavior Enhances Drug Reduction of Incontinence (BE-DRI) study. Contemporary clinical trials. 2007:48-58. Not associative hypothesis tested. [pmid: 16919506].
3170 Ushiroyama T, Ikeda A, Ueki M. Prevalence, incidence, and awareness in the treatment of menopausal urinary incontinence. Maturitas. Oct. 24. 1999;33(2):127-32. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10597876].
3171 Ushiroyama T, Ikeda A, Ueki M. Clinical efficacy of clenbuterol and propiverine in menopausal women with urinary incontinence: improvement in quality of life. J Med. 2000;31(5–6):311-9. Not eligible exposure. [pmid: 11508324].
3172 Ustun Y, Engin-Ustun Y, Gungor M, et al. Tension-free vaginal tape compared with laparoscopic Burch urethropexy. J Am Assoc Gynecol Laparosc. Aug. 2003;10(3):386-9. Not eligible exposure. [pmid: 14567818].
3173 Ustün Y, Engin-Ustün Y, Güngör M, et al. Randomized comparison of Burch urethropexy procedures concomitant with gynecologic operations. Gynecologic and obstetric investigation. 2005:19-23. Not eligible exposure. [pmid: 15627777].
3174 Vahtera T, Haaranen M, Viramo-Koskela AL, et al. Pelvic floor rehabilitation is effective in patients with multiple sclerosis. Clinical rehabilitation. 1997:211-9. Not eligible taret population. [pmid: 9360033].
3175 Vaidyananthan S, Soni BM, Brown E, et al. Effect of intermittent urethral catheterization and oxybutynin bladder instillation on urinary continence status and quality of life in a selected group of spinal cord injury patients with neuropathic bladder dysfunction. Spinal Cord. Jun. 1998;36(6):409-14. Not eligible target population. [pmid: 9648197].
3176 Vaidyanathan S, Soni BM, Sett P, et al. Flawed trial of micturition in cervical spinal cord injury patients: guidelines for trial of voiding in men with tetraplegia. Spinal Cord. Dec. 2003;41(12):667-72. Not eligible target population. [pmid: 14639445].
3177 Valencic M, Spanjol J, Maricic A, et al. Cystocoele and sensory urgency--our experience. Coll Antropol. Oct. 2008;32(Suppl 2):207-9. Not eligible target population. [pmid: 19138026].
3178 Valerius AJ. Quality of life tools for assessment of urinary incontinence. Urol Nurs. Sep. 1997;17(3):104-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9349046].
3179 Valpas A, Kivela A, Penttinen J, et al. Tension-free vaginal tape and laparoscopic mesh colposuspension in the treatment of stress urinary incontinence: immediate outcome and complications--a randomized clinical trial. Acta Obstet Gynecol Scand. Jul. 2003;82(7):665-71. Not eligible exposure. [pmid: 12790850].
3180 Valpas A, Kivela A, Penttinen J, et al. Tension-free vaginal tape and laparoscopic mesh colposuspension for stress urinary incontinence. Obstet Gynecol. Jul. 2004;104(1):42-9. Not eligible exposure. [pmid: 15228999].
3181 Valpas A, Rissanen P, Kujansuu E, et al. A cost-effectiveness analysis of tension-free vaginal tape versus laparoscopic mesh colposuspension for primary female stress incontinence. Acta Obstet Gynecol Scand. 2006;85(12):1485-90. Not eligible exposure. [pmid: 17260226].
3182 Valtonen K, Karlsson AK, Siosteen A, et al. Satisfaction with sexual life among persons with traumatic spinal cord injury and meningomyelocele. Disabil Rehabil. Aug. 30. 2006;28(16):965-76. Not eligible target population. [pmid: 16882636].
3183 van Andel G, Bottomley A, Fossa SD, et al. An international field study of the EORTC QLQ-PR25: a questionnaire for assessing the health-related quality of life of patients with prostate cancer. Eur J Cancer. Nov. 2008;44(16):2418-24. Not eligible target population. [pmid: 18774706].
3184 Van Andel G, Visser AP, Hulshof MC, et al. Health-related quality of life and psychosocial factors in patients with prostate cancer scheduled for radical prostatectomy or external radiation therapy. BJU Int. Aug. 2003;92(3):217-22. Not eligible target population. [pmid: 12887470].
3185 van Andel G, Visser AP, Zwinderman AH, et al. A prospective longitudinal study comparing the impact of external radiation therapy with radical prostatectomy on health related quality of life (HRQOL) in prostate cancer patients. Prostate. Mar. 1. 2004;58(4):354-65. Not eligible target population. [pmid: 14968436].
3186 Van Arendonk KJ, Austin JC, Boyt MA, et al. Frequency of wetting is predictive of response to anticholinergic treatment in children with overactive bladder. Urology. May. 2006;67(5):1049-53. discussion 53–4. Not eligible target population. [pmid: 16698366].
3187 Van Arendonk KJ, Knudson MJ, Austin JC, et al. Improved efficacy of extended release oxybutynin in children with persistent daytime urinary incontinence converted from regular oxybutynin. Urology. Oct. 2006;68(4):862-5. Not eligible target population. [pmid: 17070368].
3188 van Balken MR, Vandoninck V, Messelink BJ, et al. Percutaneous tibial nerve stimulation as neuromodulative treatment of chronic pelvic pain. Eur Urol. Feb. 2003;43(2):158-63. discussion 63. Not eligible target population. [pmid: 12565774].
3189 van Balken MR, Vergunst H, Bemelmans BL. Prognostic factors for successful percutaneous tibial nerve stimulation. Eur Urol. Feb. 2006;49(2):360-5. Not eligible target population. [pmid: 16359781].
3190 van Balken MR, Vergunst H, Bemelmans BL. Sexual functioning in patients with lower urinary tract dysfunction improves after percutaneous tibial nerve stimulation. Int J Impot Res. Sep–Oct. 2006;18(5):470-5. discussion 6. Not eligible target population. [pmid: 16528293].
3191 Van Brummen HJ, Bruinse HW, Van de Pol G, et al. What is the effect of overactive bladder symptoms on woman’s quality of life during and after first pregnancy?. BJU Int. Feb. 2006;97(2):296-300. Not eligible target population. [pmid: 16430633].
3192 van Brummen HJ, Bruinse HW, van de Pol G, et al. Bothersome lower urinary tract symptoms 1 year after first delivery: prevalence and the effect of childbirth. BJU Int. Jul. 2006;98(1):89-95. Not eligible target population. [pmid: 16831150].
3193 van Brummen HJ, Bruinse HW, van de Pol G, et al. The effect of vaginal and cesarean delivery on lower urinary tract symptoms: what makes the difference?. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2007;18(2):133-9. Not eligible target population. [pmid: 16628375].
3194 Van Cangh PJ, Richard F, Lorge F, et al. Adjuvant radiation therapy does not cause urinary incontinence after radical prostatectomy: results of a prospective randomized study. J Urol. Jan. 1998;159(1):164-6. Not eligible target population. [pmid: 9400462].
3195 van den Esschert JW, van Geloven AA, Vermulst N, et al. Laparoscopic ventral rectopexy for obstructed defecation syndrome. Surg Endosc. Dec. 2008;22(12):2728-32. Not eligible target population. [pmid: 18320283].
3196 van den Muijsenbergh ME, Lagro-Janssen TA. Urinary incontinence in Moroccan and Turkish women: a qualitative study on impact and preferences for treatment. Br J Gen Pract. Dec. 2006;56(533):945-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17132383].
3197 van der Linden MC, Gerretsen G, Brandhorst MS, et al. The effect of estriol on the cytology of urethra and vagina in postmenopausal women with genito-urinary symptoms. Eur J Obstet Gynecol Reprod Biol. Sep. 1993;51(1):29-33. Not eligible outcomes. [pmid: 8282140].
3198 van der Pal F, van Balken MR, Heesakkers JP, et al. Percutaneous tibial nerve stimulation in the treatment of refractory overactive bladder syndrome: is maintenance treatment necessary?. BJU Int. Mar. 2006;97(3):547-50. Level of evidence. [pmid: 16469023].
3199 van der Pal F, van Balken MR, Heesakkers JP, et al. Correlation between quality of life and voiding variables in patients treated with percutaneous tibial nerve stimulation. BJU Int. Jan. 2006;97(1):113-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16336339].
3200 van der Vaart CH, de Leeuw JR, Roovers JP, et al. The effect of urinary incontinence and overactive bladder symptoms on quality of life in young women. BJU Int. Oct. 2002;90(6):544-9. Not eligible target population. [pmid: 12230614].
3201 van der Vaart CH, de Leeuw JR, Roovers JP, et al. Measuring health-related quality of life in women with urogenital dysfunction: the urogenital distress inventory and incontinence impact questionnaire revisited. Neurourol Urodyn. 2003;22(2):97-104. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12579625].
3202 van der Vaart CH, Lamers BH, Heintz AP. Feasibility and patient satisfaction with pelvic organ prolapse and urinary incontinence day surgery. Int Urogynecol J Pelvic Floor Dysfunct. May. 2007;18(5):531-6. Not eligible Exposure. [pmid: 16932871].
3203 van der Vaart CH, van der Bom JG, de Leeuw JR, et al. The contribution of hysterectomy to the occurrence of urge and stress urinary incontinence symptoms. BJOG. Feb. 2002;109(2):149-54. Not eligible outcomes. [pmid: 11911100].
3204 van der Weide M, Smits J. Adoption of innovations by specialised nurses: personal, work and organisational characteristics. Health Policy. Apr. 2004;68(1):81-92. Not eligible outcomes. [pmid: 15033555].
3205 van Dijk MM, Mochtar CA, Wijkstra H, et al. The bell-shaped nitinol prostatic stent in the treatment of lower urinary tract symptoms: experience in 108 patients. Eur Urol. Feb. 2006;49(2):353-9. Not eligible target population. [pmid: 16426738].
3206 van Eijken M, Wensing M, de Konink M, et al. Health education on self-management and seeking health care in older adults: a randomised trial. Patient Educ Couns. Oct. 2004;55(1):48-54. Not eligible target population. [pmid: 15476989].
3207 van Gerwen M, Schellevis F, Lagro-Janssen T. Comorbidities associated with urinary incontinence: a case-control study from the Second Dutch National Survey of General Practice. J Am Board Fam Med. Nov–Dec. 2007;20(6):608-10. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17954870].
3208 van Houten P, Achterberg W, Ribbe M. Urinary incontinence in disabled elderly women: a randomized clinical trial on the effect of training mobility and toileting skills to achieve independent toileting. Gerontology. 2007;53(4):205-10. Not eligible target population. [pmid: 17347567].
3209 Van Kampen M, De Weerdt W, Van Poppel H, et al. Effect of pelvic-floor re-education on duration and degree of incontinence after radical prostatectomy: a randomised controlled trial. Lancet. Jan. 8. 2000;355(9198):98-102. Not eligible target population. [pmid: 10675166].
3210 van Leijsen SA, Kluivers KB, Mol BW, et al. Protocol for the value of urodynamics prior to stress incontinence surgery (VUSIS) study: a multicenter randomized controlled trial to assess the cost effectiveness of urodynamics in women with symptoms of stress urinary incontinence in whom surgical treatment is considered. BMC Womens Health. 2009;9:22. Not eligible target population. [pmid: 19622153].
3211 Van Oyen H, Van Oyen P. Urinary incontinence in Belgium; prevalence, correlates and psychosocial consequences. Acta Clin Belg. Jul–Aug. 2002;57(4):207-18. not eligible outcomes. [pmid: 12462797].
3212 Van Poppel H, Collette L, Kirkali Z, et al. Quality control of radical prostatectomy: a feasibility study. Eur J Cancer. May. 2001;37(7):884-91. Not eligible target population. [pmid: 11313177].
3213 van Raalte HM, Lucente VR, Molden SM, et al. One-year anatomic and quality-of-life outcomes after the Prolift procedure for treatment of posthysterectomy prolapse. Am J Obstet Gynecol. Dec. 2008;199(6):694 e1-6. Not eligible exposure. [pmid: 18986641].
3214 Van Voorhis BJ. Genitourinary symptoms in the menopausal transition. Am J Med. Dec. 19. 2005;118(Suppl 12B):47-53. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16414326].
3215 van Voskuilen AC, Oerlemans DJ, Weil EH, et al. Long term results of neuromodulation by sacral nerve stimulation for lower urinary tract symptoms: a retrospective single center study. Eur Urol. Feb. 2006;49(2):366-72. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16413105].
3216 van Waalwijk van Doorn ES, Zwiers W. Ambulant monitoring to assess the efficacy of oxybutynin chloride in patients with mixed incontinence. Eur Urol. 1990;18(1):49-51. Not eligible exposure. [pmid: 2401307].
3217 Vandoninck V, Bemelmans BL, Mazzetta C, et al. The prevalence of urinary incontinence in community-dwelling married women: a matter of definition. BJU Int. Dec. 2004;94(9):1291-5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 15610108].
3218 Vardy MD, Brodman M, Olivera CK, et al. Anterior intravaginal slingplasty tunneller device for stress incontinence and posterior intravaginal slingplasty for apical vault prolapse: a 2-year prospective multicenter study. Am J Obstet Gynecol. Jul. 2007;197(1):104 e1-8. Not eligible exposure. [pmid: 17618778].
3219 Varma MG, Brown JS, Creasman JM, et al. Fecal incontinence in females older than aged 40 years: who is at risk?. Dis Colon Rectum. Jun. 2006;49(6):841-51. Not eligible target population. [pmid: 16741640].
3220 Vasconcelos M, Lima E, Caiafa L, et al. Voiding dysfunction in children. Pelvic-floor exercises or biofeedback therapy: a randomized study. Pediatr Nephrol. Dec. 2006;21(12):1858-64. Not eligible target population. [pmid: 16967285].
3221 Vassallo BJ, Kleeman SD, Segal JL, et al. Tension-free vaginal tape: a quality-of-life assessment. Obstet Gynecol. Sep. 2002;100(3):518-24. Not eligible exposure. [pmid: 12220772].
3222 Velez JB. Behavior therapy for urge incontinence in older women. J Fam Pract. Mar. 1999;48(3):168-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10086751].
3223 Venus JT, Calhoun BC. Urinary incontinence procedures performed at a military teaching hospital. Mil Med. Dec. 1995;160(12):613-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8775384].
3224 Verhoef M, Barf HA, Post MW, et al. Functional independence among young adults with spina bifida, in relation to hydrocephalus and level of lesion. Dev Med Child Neurol. Feb. 2006;48(2):114-9. Not eligible target population. [pmid: 16417666].
3225 Verhoef M, Lurvink M, Barf HA, et al. High prevalence of incontinence among young adults with spina bifida: description, prediction and problem perception. Spinal Cord. Jun. 2005;43(6):331-40. Not eligible target population. [pmid: 15685262].
3226 Vernarec E. The high costs of hidden conditions. Bus Health. Jan. 1998;16(1):19-23. Not eligible exposure. [pmid: 10176562].
3227 Versi E. Incontinence in the climacteric. Clin Obstet Gynecol. Jun. 1990;33(2):392-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 2350922].
3228 Vervest HA, Bisseling TM, Heintz AP, et al. The prevalence of voiding difficulty after TVT, its impact on quality of life, and related risk factors. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2007;18(2):173-82. Not eligible exposure. [pmid: 16633883].
3229 Vianello A, Costantini E, Del Zingaro M, et al. Mini-invasive techniques for the treatment of female stress urinary incontinence. Minerva Ginecol. Dec. 2007;59(6):557-69. Not eligible exposure. [pmid: 18043568].
3230 Vickerman J. The role of the occupational therapist in continence care. Nurs Times. Apr. 23–29. 2002;98(17):52. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12008266].
3231 Vickerman J. The benefits of a lending library for female urinals. Nurs Times. Nov. 4–10. 2003;99(44):56-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14649145].
3232 Vickerman J. Selecting urinals for male patients. Nurs Times. May. 9–15. 2006;102(19):47-8. Not eligible target population. [pmid: 16711290].
3233 Viereck V, Bader W, Krauss T, et al. Intra-operative introital ultrasound in Burch colposuspension reduces post-operative complications. BJOG. Jun. 2005;112(6):791-6. Not eligible exposure. [pmid: 15924539].
3234 Viereck V, Pauer HU, Bader W, et al. Introital ultrasound of the lower genital tract before and after colposuspension: a 4-year objective follow-up. Ultrasound Obstet Gynecol. Mar. 2004;23(3):277-83. Not eligible exposure. [pmid: 15027018].
3235 Vigod SN, Stewart DE. Treatment patterns in Canadian women with urinary incontinence: a need to improve case identification. J Womens Health (Larchmt). Jun. 2007;16(5):707-12. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17627406].
3236 Vinker S, Kaplan B, Nakar S, et al. Urinary incontinence in women: prevalence, characteristics and effect on quality of life. A primary care clinic study. Isr Med Assoc J. Sep. 2001;3(9):663-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11574982].
3237 Vinsnes AG, Haltbakk J, Hunskaar S. A Norwegian version of the Incontinence Stress Questionnaire-Staff Reaction: translation and validation for cross-cultural use. J Nurs Meas. Summer. 2000;8(1):71-86. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11026167].
3238 Vinsnes AG, Harkless GE, Haltbakk J, et al. Healthcare personnel’s attitudes towards patients with urinary incontinence. J Clin Nurs. Jul. 2001;10(4):455-62. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11822493].
3239 Vironen JH, Kairaluoma M, Aalto AM, et al. Impact of functional results on quality of life after rectal cancer surgery. Dis Colon Rectum. May. 2006;49(5):568-78. Not eligible target population. [pmid: 16583289].
3240 Visco AG, Brubaker L, Nygaard I, et al. The role of preoperative urodynamic testing in stress-continent women undergoing sacrocolpopexy: the Colpopexy and Urinary Reduction Efforts (CARE) randomized surgical trial. Int Urogynecol J Pelvic Floor Dysfunct. May. 2008;19(5):607-14. Not eligible exposure. [pmid: 18185903].
3241 Visco AG, Weidner AC, Cundiff GW, et al. Observed patient compliance with a structured outpatient bladder retraining program. Am J Obstet Gynecol. Dec. 1999;181(6):1392-4. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10601918].
3242 Viseshsindh W, Kochakarn W, Waikakul W, et al. A randomized controlled trial of pubovaginal sling versus vaginal wall sling for stress urinary incontinence. J Med Assoc Thai. Apr. 2003;86(4):308-15. Not eligible exposure. [pmid: 12757074].
3243 Volk RJ, Cantor SB, Cass AR, et al. Preferences of husbands and wives for outcomes of prostate cancer screening and treatment. J Gen Intern Med. Apr. 2004;19(4):339-48. Not eligible target population. [pmid: 15061743].
3244 Volkan T, Ihsan TA, Yilmaz O, et al. Short term outcomes of high power (80 W) potassium-titanyl-phosphate laser vaporization of the prostate. Eur Urol. Oct. 2005;48(4):608-13. Not eligible target population. [pmid: 16135396].
3245 von Gontard A, Lettgen B, Olbing H, et al. Behavioural problems in children with urge incontinence and voiding postponement: a comparison of a paediatric and child psychiatric sample. Br J Urol. May. 1998;81(Suppl 3):100-6. Not eligible target population. [pmid: 9634031].
3246 von Pechmann WS, Mutone M, Fyffe J, et al. Total colpocleisis with high levator plication for the treatment of advanced pelvic organ prolapse. Am J Obstet Gynecol. Jul. 2003;189(1):121-6. Not eligible exposure. [pmid: 12861149].
3247 Voorham-van der Zalm PJ, Lycklama ANGA, Elzevier HW, et al. “Diagnostic investigation of the pelvic floor”: a helpful tool in the approach in patients with complaints of micturition, defecation, and/or sexual dysfunction. J Sex Med. Apr. 2008;5(4):864-71. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18221287].
3248 Voorham-van der Zalm PJ, Pelger RC, Stiggelbout AM, et al. Effects of magnetic stimulation in the treatment of pelvic floor dysfunction. BJU Int. May. 2006;97(5):1035-8. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16643487].
3249 Wadie BS, Edwan A, Nabeeh AM. Autologous fascial sling vs polypropylene tape at short-term followup: a prospective randomized study. J Urol. Sep. 2005;174(3):990-3. Not eligible target population. [pmid: 16094020].
3250 Wagg A, Bayliss M, Ingham NJ, et al. Urodynamic variables cannot be used to classify the severity of detrusor instability. Br J Urol. Oct. 1998;82(4):499-502. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9806177].
3251 Wagg A, Das Gupta R, Assassa P, et al. Secondary-care treatment patterns in the UK for women with urinary incontinence. BJU Int. 2005;96:839-42. Not eligible outcomes. [pmid: 16153213].
3252 Wagg A, Lowe D, Peel P, et al. Continence care for older people in England and Wales: data from a national audit. J Wound Ostomy Continence Nurs. Mar–Apr. 2008;35(2):215-20. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18344798].
3253 Wagg A, Mian S, Lowe D, et al. National audit of continence care for older people: results of a pilot study*. J Eval Clin Pract. Dec. 2005;11(6):525-32. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16364105].
3254 Wakavaiachi VM, Girao MJ, Sartori MG, et al. Changes in the lower urinary tract in continent women and in women with stress urinary incontinence, according to menopausal status. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(3):156-60. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11451002].
3255 Walker GT, Texter JH Jr. Success and patient satisfaction following the Stamey procedure for stress urinary incontinence. J Urol. Jun. 1992;147(6):1521-3. Not eligible exposure. [pmid: 1593680].
3256 Wall LL, Copas P, Galloway NT. Use of a pedicled rectus abdominis muscle flap sling in the treatment of complicated stress urinary incontinence. Am J Obstet Gynecol. Dec. 1996;175(6):1460-4. discussion 4–6. Not eligible exposure. [pmid: 8987925].
3257 Wallwiener D, Grischke EM, Rimbach S, et al. Endoscopic retropubic colposuspension: “Retziusscopy” versus laparoscopy--a reasonable enlargement of the operative spectrum in the management of recurrent stress incontinence?. Endosc Surg Allied Technol. Apr–Jun. 1995;3(2–3):115-8. Not eligible exposure. [pmid: 7552124].
3258 Walsh IK, Nambirajan T, Donellan SM, et al. Cadaveric fascia lata pubovaginal slings: early results on safety, efficacy and patient satisfaction. BJU Int. Sep. 2002;90(4):415-9. Not eligible exposure. [pmid: 12175399].
3259 Walsh IK, Williams SG, Mahendra V, et al. Artificial urinary sphincter implantation in the irradiated patient: safety, efficacy and satisfaction. BJU Int. Mar. 2002;89(4):364-8. Not eligible target population. [pmid: 11872025].
3260 Walsh K, Generao SE, White MJ, et al. The influence of age on quality of life outcome in women following a tension-free vaginal tape procedure. J Urol. Mar. 2004;171(3):1185-8. Not eligible exposure. [pmid: 14767297].
3261 Walsh PC. Radical prostatectomy for localized prostate cancer provides durable cancer control with excellent quality of life: a structured debate. J Urol. Jun. 2000;163(6):1802-7. Not eligible target population. [pmid: 10799186].
3262 Walsh PC, Marschke P, Ricker D, et al. Patient-reported urinary continence and sexual function after anatomic radical prostatectomy. Urology. Jan. 2000;55(1):58-61. Not eligible target population. [pmid: 10654895].
3263 Walsh PC, Marschke PL. Intussusception of the reconstructed bladder neck leads to earlier continence after radical prostatectomy. Urology. Jun. 2002;59(6):934-8. Not eligible target population. [pmid: 12031385].
3264 Walsh PC, Partin AW, Epstein JI. Cancer control and quality of life following anatomical radical retropubic prostatectomy: results at 10 years. J Urol. Nov. 1994;152(5 Pt 2):1831-6. Not eligible target population. [pmid: 7523730].
3265 Walter AJ, Morse AN, Hammer RA, et al. Laparoscopic versus open Burch retropubic urethropexy: comparison of morbidity and costs when performed with concurrent vaginal prolapse repairs. Am J Obstet Gynecol. Apr. 2002;186(4):723-8. Not eligible exposure. [pmid: 11967498].
3266 Waltregny D, Gaspar Y, Reul O, et al. TVT-O for the treatment of female stress urinary incontinence: results of a prospective study after a 3-year minimum follow-up. Eur Urol. Feb. 2008;53(2):401-8. Not eligible exposure. [pmid: 17728052].
3267 Waltregny D, Leruth J, de Leval J. The inside-Out Transobturator Sling for the Surgical Treatment of Post-Radical Prostatectomy Urinary Incontinence: Interim Results of a Prospective, Observational Study after a 1-Year Minimum Follow-Up. Paper presented at: 39th Annual Meeting of the International Continence Society (ICS 2009). Moscone West, San Francisco. 29 Sep –3 Oct 2009. Not eligible target population.
3268 Waltregny D, Reul O, Mathantu B, et al. Inside out transobturator vaginal tape for the treatment of female stress urinary incontinence: interim results of a prospective study after a 1-year minimum followup. J Urol. Jun. 2006;175(6):2191-5. Not eligible exposure. [pmid: 16697838].
3269 Wang AC, Chen MC. Randomized comparison of local versus epidural anesthesia for tension-free vaginal tape operation. J Urol. Apr. 2001;165(4):1177-80. Not eligible exposure. [pmid: 11257665].
3270 Wang AC, Chen MC. Comparison of tension-free vaginal taping versus modified Burch colposuspension on urethral obstruction: a randomized controlled trial. Neurourol Urodyn. 2003;22(3):185-90. Not eligible exposure. [pmid: 12707868].
3271 Wang AC, Chen MC. The correlation between preoperative voiding mechanism and surgical outcome of the tension-free vaginal tape procedure, with reference to quality of life. BJU Int. Apr. 2003;91(6):502-6. Not eligible exposure. [pmid: 12656903].
3272 Wang AC, Lin YH, Tseng LH, et al. Prospective randomized comparison of transobturator suburethral sling (Monarc) vs suprapubic arc (Sparc) sling procedures for female urodynamic stress incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Sep. 2006;17(5):439-43. Not eligible exposure. [pmid: 16328116].
3273 Wang F, Song Y, Huang H. Prospective randomized trial of TVT and TOT as primary treatment for female stress urinary incontinence with or without pelvic organ prolapse in Southeast China. Arch Gynecol Obstet. Feb. 2010;281(2):279-86. Not eligible exposure. [pmid: 19404656].
3274 Wang J, Kane RL, Eberly LE, et al. The effects of resident and nursing home characteristics on activities of daily living. J Gerontol A Biol Sci Med Sci. Apr. 2009;64(4):473-80. Not eligible target population. [pmid: 19201787].
3275 Wang P, Luthin GR, Ruggieri MR. Muscarinic acetylcholine receptor subtypes mediating urinary bladder contractility and coupling to GTP binding proteins. J Pharmacol Exp Ther. May. 1995;273(2):959-66. Not eligible target population. [pmid: 7752101].
3276 Wang W, Zhu L, Lang J. Transobturator tape procedure versus tension-free vaginal tape for treatment of stress urinary incontinence. International Journal of Gynaecology & Obstetrics. Feb. 2009;104(2):113-6. Not eligible exposure. [pmid: 18957269].
3277 Ward K, Hilton P, United K, et al. Prospective multicentre randomised trial of tension-free vaginal tape and colposuspension as primary treatment for stress incontinence. BMJ. Clinical research ed. 2002;67. Not eligible exposure.
3278 Ward KL, Hilton P. A prospective multicenter randomized trial of tension-free vaginal tape and colposuspension for primary urodynamic stress incontinence: two-year follow-up. Am J Obstet Gynecol. Feb. 2004;190(2):324-31. Not eligible exposure. [pmid: 14981369].
3279 Ward KL, Hilton P. Tension-free vaginal tape versus colposuspension for primary urodynamic stress incontinence: 5-year follow up. BJOG. Jan. 2008;115(2):226-33. Not eligible exposure. [pmid: 17970791].
3280 Warming L, Christoffersen C, Riis BJ, et al. Adverse effects of a SERM (Levormeloxifene). Safety parameters and bone mineral density 12 months after treatment withdrawal. Maturitas. Mar. 28. 2003;44(3):189-99. Not eligible target population. [pmid: 12648882].
3281 Warner JP, Harvey CA, Barnes TR. Clozapine and urinary incontinence. Int Clin Psychopharmacol. Sep. 1994;9(3):207-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7814831].
3282 Warnke A, Meyer G, Bender R, et al. Predictors of adherence to the use of hip protectors in nursing home residents. J Am Geriatr Soc. Mar. 2004;52(3):340-5. Not eligible target population. [pmid: 14962146].
3283 Wasserberg N, Haney M, Petrone P, et al. Fecal incontinence among morbid obese women seeking for weight loss surgery: an underappreciated association with adverse impact on quality of life. Int J Colorectal Dis. May. 2008;23(5):493-7. Not eligible target population. [pmid: 18228028].
3284 Wasserberg N, Haney M, Petrone P, et al. Morbid obesity adversely impacts pelvic floor function in females seeking attention for weight loss surgery. Dis Colon Rectum. Dec. 2007;50(12):2096-103. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17899277].
3285 Wasserberg N, Kaiser AM, Nunoo-Mensah JW, et al. Preservation of bowel and urinary continence in the management of locally recurrent rectal cancer. J Surg Oncol. Oct. 1. 2005;92(1):76-81. Not eligible target population. [pmid: 16180216].
3286 Wasson JH, Reda DJ, Bruskewitz RC, et al. A comparison of transurethral surgery with watchful waiting for moderate symptoms of benign prostatic hyperplasia. The Veterans Affairs Cooperative Study Group on Transurethral Resection of the Prostate. N Engl J Med. Jan. 12. 1995;332(2):75-9. Not eligible target population. [pmid: 7527493].
3287 Watanabe T, Vaccaro AR, Kumon H, et al. High incidence of occult neurogenic bladder dysfunction in neurologically intact patients with thoracolumbar spinal injuries. J Urol. Mar. 1998;159(3):965-8. Not eligible target population. [pmid: 9474194].
3288 Watson AJ, Currie I, Jarvis GJ. A prospective placebo controlled double blind randomised study to investigate the use of indoramin to prevent post-operative voiding disorders after surgical treatment for genuine stress incontinence. Br J Obstet Gynaecol. Mar. 1999;106(3):270-2. Not eligible exposure. [pmid: 10426648].
3289 Watson NM. Advancing quality of urinary incontinence evaluation and treatment in nursing homes through translational research. Worldviews Evid Based Nurs. 2004;1(Suppl 1):S21-5. Not eligible target population. [pmid: 17129331].
3290 Watson NM, Brink CA, Zimmer JG, et al. Use of the Agency for Health Care Policy and Research Urinary Incontinence Guideline in nursing homes. J Am Geriatr Soc. Dec. 2003;51(12):1779-86. Not eligible target population. [pmid: 14687358].
3291 Wattanayingcharoenchai R, Manonai J, Vannatim N, et al. Impact of stress urinary incontinence and overactive bladder on quality of life in Thai women attending the urogynecology clinic. J Med Assoc Thai. Jan. 2007;90(1):26-31. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17621729].
3292 Weatherall M, Arnold T. New Zealand Nocturia Guideline C. Nocturia in adults: draft New Zealand guidelines for its assessment and management in primary care. New Zealand Medical Journal. 2006;119(1234):U1976. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16718287].
3293 Weatherall M, Slow T, Wiltshire K. Risk factors for entry into residential care after a support-needs assessment. N Z Med J. Sep. 24. 2004;117(1202):U1075. Not eligible target population. [pmid: 15477909].
3294 Weaver A, Jacques E. Encouraging adolescents to seek continence help. Nurs Times. Nov. 18–24. 2008;104(46):46-8. Not eligible target population. [pmid: 19054972].
3295 Webber EM, Crofts PG, Pomeroy C, et al. Augmentation ileocystoplasty in children with myelodysplasia. Can J Surg. Apr. 1990;33(2):135-8. Not eligible target population. [pmid: 2268813].
3296 Weber AM, Walters MD. Cost-effectiveness of urodynamic testing before surgery for women with pelvic organ prolapse and stress urinary incontinence. Am J Obstet Gynecol. Dec. 2000;183(6):1338-46. discussion 46–7. no associative hypothesis tested. [pmid: 11120494].
3297 Weber AM, Walters MD, Schover LR, et al. Functional outcomes and satisfaction after abdominal hysterectomy. Am J Obstet Gynecol. Sep. 1999;181(3):530-5. Not eligible target population. [pmid: 10486459].
3298 Weber AM, Walters MD, Schover LR, et al. Sexual function in women with uterovaginal prolapse and urinary incontinence. Obstet Gynecol. Apr. 1995;85(4):483-7. Not eligible exposure. [pmid: 7898820].
3299 Weber BA, Roberts BL, Chumbler NR, et al. Urinary, sexual, and bowel dysfunction and bother after radical prostatectomy. Urol Nurs. Dec. 2007;27(6):527-33. not eligible target population. [pmid: 18217536].
3300 Weber BA, Roberts BL, McDougall GJ Jr. Exploring the efficacy of support groups for men with prostrate cancer. Geriatr Nurs. Sep–Oct. 2000;21(5):250-3. Not eligible target population. [pmid: 11035307].
3301 Weber BA, Roberts BL, Resnick M, et al. The effect of dyadic intervention on self-efficacy, social support, and depression for men with prostate cancer. Psychooncology. Jan. 2004;13(1):47-60. Not eligible target population. [pmid: 14745745].
3302 Weese DL, Roskamp DA, Leach GE, et al. Intravesical oxybutynin chloride: experience with 42 patients. Urology. Jun. 1993;41(6):527-30. Not eligible target population. [pmid: 8516987].
3303 Wehrmacher WH, Bellows RT. Women’s health: meeting the challenges of primary care in the age of managed care. Compr Ther. Summer. 2002;28(2):145-7. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 12085463].
3304 Wei JT, Dunn RL, Sandler HM, et al. Comprehensive comparison of health-related quality of life after contemporary therapies for localized prostate cancer. J Clin Oncol. Jan. 15. 2002;20(2):557-66. Not eligible target population. [pmid: 11786586].
3305 Wei JT, Montie JE. Comparison of patients’ and physicians’ rating of urinary incontinence following radical prostatectomy. Semin Urol Oncol. Feb. 2000;18(1):76-80. Not eligible target population. [pmid: 10719937].
3306 Wein AJ. Oral and intravaginal estrogens alone and in combination with alpha-adrenergic stimulation in genuine stress incontinence. J Urol. Dec. 1991;146(6):1670-1. Not eligible exposure. [pmid: 1942363].
3307 Wein AJ. Percutaneous tibial nerve stimulation in the treatment of overactive bladder: urodynamic data. J Urol. Sep. 2003;170(3):1051. Comment. [pmid: 12926433].
3308 Wein AJ. Antidiuresis: a new concept in managing female daytime urinary incontinence. J Urol. Jun. 2005;173(6):2054-5. Not eligible exposure. [pmid: 15879824].
3309 Wein AJ. Treatment of urge-predominant mixed urinary incontinence with tolterodine extended release: a randomized, placebo-controlled trial. J Urol. Jun. 2005;173(6):2056-7. Comment. [pmid: 15879827].
3310 Wein AJ. Mixed incontinence. J Urol. Jun. 2005;173(6):2055-7. Comment. [pmid: 15879826].
3311 Wein AJ. Transvaginal surgery in the octogenarian using cadaveric fascia for pelvic prolapse and stress incontinence: minimal one-year results compared to younger patients. J Urol. Sep. 2005;174(3):1009. Not eligible exposure. [pmid: 16094028].
3312 Wein AJ. The effects of the tension-free vaginal tape on voiding function: a prospective evaluation. J Urol. Sep. 2005;174(3):1010. Not eligible exposure. [pmid: 16094030].
3313 Wein AJ. Tension-free vaginal tape: do patients who fail to follow-up have the same results as those who do?. J Urol. Sep. 2005;174(3):1009-10. Not eligible exposure. [pmid: 16094027].
3314 Wein AJ, Rovner ES. Definition and epidemiology of overactive bladder. Urology. Nov. 2002;60(5 Suppl 1):7-12. discussion 12493342. no associative hypothesis tested. [pmid: 12493342].
3315 Weinberger MW, Goodman BM, Carnes M. Long-term efficacy of nonsurgical urinary incontinence treatment in elderly women. J Gerontol A Biol Sci Med Sci. Mar. 1999;54(3):M117-21. Case-series. [pmid: 10191838].
3316 Weiss JP, Blaivas JG, Jones M, et al. Age related pathogenesis of nocturia in patients with overactive bladder. J Urol. Aug. 2007;178(2):548-51. discussion 51. Not eligible target population. [pmid: 17570424].
3317 Wells M. Are we meeting clients’ needs? Nursing audit in continence care. Prof Nurse. Apr. 1993;8(7):430-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 8475147].
3318 Wells M. Continence. Achieving good care. Nurs Times. Oct 26-Nov 1. 1994;90(43):68. Comment. [pmid: 7984467].
3319 Wells M. Managing urinary incontinence with BioDerm external continence device. Br J Nurs. May. 8–21. 2008;17(9):s24-9. Not eligible target population. [pmid: 18567167].
3320 Wells M, Wagg A. Integrated continence services and the female Bangladeshi population. Br J Nurs. May. 10–23. 2007;16(9):516-9. Not eligible target population. [pmid: 17551440].
3321 Wells TJ. Managing incontinence through managing the environment. Urol Nurs. Jun. 1992;12(2):48-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 1609308].
3322 Wells TJ. Nursing research on urinary incontinence. Urol Nurs. Sep. 1994;14(3):109-12. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 7732410].
3323 Welz-Barth A, Fusgen I, Melchior HJ. rerun of the 1996 German Urinary Incontinence Survey: will doctors ever ask?. World J Urol. 2000. Dec. 1999;18(6):436-8. no associative hypothesis tested. [pmid: 11204265].
3324 Wen Y, Man WC, Sokol ER, et al. Is alpha2-macroglobulin important in female stress urinary incontinence?. Hum Reprod. Feb. 2008;23(2):387-93. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 18077315].
3325 Wen Y, Polan ML, Chen B. Do extracellular matrix protein expressions change with cyclic reproductive hormones in pelvic connective tissue from women with stress urinary incontinence?. Hum Reprod. May. 2006;21(5):1266-73. Not eligible exposure. [pmid: 16452154].
3326 Wen Y, Zhao YY, Polan ML, et al. Effect of relaxin on TGF-beta1 expression in cultured vaginal fibroblasts from women with stress urinary incontinence. Reprod Sci. Apr. 2008;15(3):312-20. Not eligible exposure. [pmid: 18421026].
3327 Wenger NS, Roth CP, Shekelle PG, et al. A practice-based intervention to improve primary care for falls, urinary incontinence, and dementia. J Am Geriatr Soc. Mar. 2009;57(3):547-55. Not eligible outcomes. [pmid: 19175441].
3328 Wennberg AL, Edlund C, Fall M, et al. Stamey’s abdominovaginal needle colposuspension for the correction of female genuine stress urinary incontinence--long-term results. Scand J Urol Nephrol. 2003;37(5):419-23. Not eligible exposure. [pmid: 14594692].
3329 Wheeler V. A new kind of loving? The effect of continence problems on sexuality. Prof Nurse. Jun. 1990;5(9):492-6. Comment. [pmid: 2367544].
3330 White H. Designer gear. Nurs Times. May. 5–11. 1999;95(18):69-70. 3. 6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10373916].
3331 White M. No longer a poor relation. Nurs Stand. Jun. 7–13. 2000;14(38):59. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11974304].
3332 Whiteside JL, Ensrud-Bowlin KM, Wang G, et al. Lead placement and associated nerve distribution of an implantable periurethral electrostimulator. Int Urogynecol J Pelvic Floor Dysfunct. Mar. 2009;20(3):325-9. Not eligible target population. [pmid: 19052686].
3333 Whiteside JL, Hijaz A, Imrey PB, et al. Reliability and agreement of urodynamics interpretations in a female pelvic medicine center. Obstet Gynecol. Aug. 2006;108(2):315-23. no associated hypothesis tested. [pmid: 16880301].
3334 Whitford HM, Alder B, Jones M. A longitudinal follow up of women in their practice of perinatal pelvic floor exercises and stress urinary incontinence in North-East Scotland. Midwifery. Sep. 2007;23(3):298-308. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17049694].
3335 Whitford HM, Alder B, Jones M. A cross-sectional study of knowledge and practice of pelvic floor exercises during pregnancy and associated symptoms of stress urinary incontinence in North-East Scotland. Midwifery. Jun. 2007;23(2):204-17. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17197060].
3336 Wielink G, Essink-Bot ML, van Kerrebroeck PE, et al. Sacral rhizotomies and electrical bladder stimulation in spinal cord injury. 2. Cost-effectiveness and quality of life analysis. Dutch Study Group on Sacral Anterior Root Stimulation. Eur Urol. 1997;31(4):441-6. Not eligible exposure. [pmid: 9187905].
3337 Wiener JS, Scales MT, Hampton J, et al. Long-term efficacy of simple behavioral therapy for daytime wetting in children. J Urol. Sep. 2000;164(3 Pt 1):786-90. Not eligible target population. [pmid: 10953156].
3338 Wiersma R. Overview of bladder exstrophy: a third world perspective. J Pediatr Surg. Aug. 2008;43(8):1520-3. Not eligible target population. [pmid: 18675645].
3339 Wijma J, Potters AE, de Wolf BT, et al. Anatomical and functional changes in the lower urinary tract following spontaneous vaginal delivery. BJOG. Jul. 2003;110(7):658-63. Not eligible target population. [pmid: 12842056].
3340 Wijma J, Weis Potters AE, de Wolf BT, et al. Anatomical and functional changes in the lower urinary tract during pregnancy. BJOG. Jul. 2001;108(7):726-32. Not eligible target population. [pmid: 11467699].
3341 Wilbur J, Miller AM, Montgomery A, et al. Sociodemographic characteristics, biological factors, and symptom reporting in midlife women. Menopause. Spring. 1998;5(1):43-51. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9689194].
3342 Wilcox DT. The management of urinary incontinence in the exstrophy complex, posterior urethral valves, and infrasphincteric ureters. Semin Pediatr Surg. May. 2002;11(2):128-33. Not eligible target population. [pmid: 11973765].
3343 Wilkinson E. Urinary incontinence in women. Nurs Times. Nov 28-Dec 4. 2006;102(48):23-4. no primary result. [pmid: 17193773].
3344 Wilkinson K. Pakistani women’s perceptions and experiences of incontinence. Nurs Stand. Oct. 17–23. 2001;16(5):33-9. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11977796].
3345 Wille S, Sobottka A, Heidenreich A, et al. Pelvic floor exercises, electrical stimulation and biofeedback after radical prostatectomy: results of a prospective randomized trial. J Urol. Aug. 2003;170(2 Pt 1):490-3. Not eligible target population. [pmid: 12853806].
3346 Willener R, Hantikainen V. Individual quality of life following radical prostatectomy in men with prostate cancer. Urol Nurs. Apr. 2005;25(2):88-90. 5. 100. Not eligible target population. [pmid: 15900977].
3347 Williams A, Herron-Marx S, Carolyn H. The prevalence of enduring postnatal perineal morbidity and its relationship to perineal trauma. Midwifery. Dec. 2007;23(4):392-403. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17196714].
3348 Williams A, Herron-Marx S, Knibb R. The prevalence of enduring postnatal perineal morbidity and its relationship to type of birth and birth risk factors. J Clin Nurs. Mar. 2007;16(3):549-61. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 17335531].
3349 Williams C, Lorton L. Attends Slip with S-form: a new design of an all-in-one product. Br J Nurs. Apr 27–May 10. 2006;15(8):440-3. Not eligible target population. [pmid: 16723950].
3350 Williams ER, Malone PS. The social implications of lower urinary tract reconstruction performed during childhood. Br J Urol. Aug. 1995;76(2):226-30. Not eligible target population. [pmid: 7663916].
3351 Williams JG, Cheung WY, Cohen DR, et al. Can randomised trials rely on existing electronic data? A feasibility study to explore the value of routine data in health technology assessment. Health Technol Assess. v. 2003;7(26):iii-x. 1. 117. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 14499049].
3352 Williams K. Good practice guidance for continence services. Br J Nurs. May. 11–24. 2000;9(9):530. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 11904884].
3353 Williams KS, Assassa RP, Smith NK, et al. Educational preparation: specialist practice in continence care. Br J Nurs. Oct. 14–27. 1999;8(18):1198-207. 202, 204 passim. Not eligible outcomes. [pmid: 10897707].
3354 Williams MA, Noe HN, Smith RA. The importance of urinary tract infection in the evaluation of the incontinent child. J Urol. Jan. 1994;151(1):188-90. Not eligible target population. [pmid: 8254811].
3355 Willis J. Intermittent catheters. Prof Nurse. May. 1995;10(8):523-4. 7. 8. Comment. [pmid: 7761495].
3356 Willis J. Consumer choice in continence products. Nurs Times. Mar 26–Apr 1. 1997;93(13):64-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 9128591].
3357 Willis J. The future beckons. Nurs Times. May. 5–11. 1999;95(18):61-2. 5. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10373914].
3358 Willis J. Continence. Geared up for guidance. Nurs Times. Oct. 20–26. 1999;95(42):70-2. Comment. [pmid: 10788894].
3359 Wilson CM, Williams BJ, Bilello S, et al. Bovine dermis: a novel biologic substitute for autologous tissue in sling surgery. Int Urogynecol J Pelvic Floor Dysfunct. Dec. 2008;19(12):1671-6. Not eligible exposure. [pmid: 18690401].
3360 Wilson L, Brown JS, Shin GP, et al. Annual direct cost of urinary incontinence. Obstet Gynecol. Sep. 2001;98(3):398-406. Not eligible outcomes. [pmid: 11530119].
3361 Wilson LC, Gilling PJ, Williams A, et al. A randomised trial comparing holmium laser enucleation versus transurethral resection in the treatment of prostates larger than 40 grams: results at 2 years. Eur Urol. Sep. 2006;50(3):569-73. Not eligible target population. [pmid: 16704894].
3362 Wilson PD, Herbison GP. A randomized controlled trial of pelvic floor muscle exercises to treat postnatal urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(5):257-64. Not eligible target population. [pmid: 9849757].
3363 Winder A. Incontinence: why women are still suffering in silence. Community Nurse. Oct. 1998;4(9):15-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 10326364].
3364 Winder A. Antimuscarinic management of overactive bladder. Br J Community Nurs. Jul. 2005;10(7):313-6. Did not provide comparative assessment of the outcomes among different treatments for female UI. [pmid: 16010231].
3365 Winkler HA, Sand PK. Treatment of detrusor instability with oxybutynin rectal suppositories. Int Urogynecol J Pelvic Floor Dysfunct. 1998;9(2):100-2. Not eligible target population. [pmid: 9694139].
3366 Winters JC, Chiverton A, Scarpero HM, et al. Collagen injection therapy in elderly women: long-term results and patient satisfaction. Urology. Jun. 2000;55(6):856-61. Not eligible outcomes. [pmid: 10840091].
3367 Winton AL, Eastwood J, Powell MC, et al. An evaluation of conscious sedation using propofol and remifentanil for tension-free vaginal tape insertion. Anaesthesia. Sep. 2008;63(9):932-7. Not eligible exposure. [pmid: 18616523].
3368 Wiseman PA, Malone-Lee J, Rai GS. Terodiline with bladder retraining for treating detrusor instability in elderly people. BMJ. Apr. 27. 1991;302(6783):994-6. Not eligible exposure. [pmid: 2039897].
3369 Withagen MI, Milani AL. Which factors influenced the result of a tension free vaginal tape operation in a single teaching hospital?. Acta Obstetricia et Gynecologica Scandinavica. 2007;86(9):1136-9. Not eligible target population. [pmid: 17712658].
3370 Woldringh C, van den Wijngaart M, Albers-Heitner P, et al. Pelvic floor muscle training is not effective in women with UI in pregnancy: a randomised controlled trial. Int Urogynecol J Pelvic Floor Dysfunct. Apr. 2007;18(4):383-90. Not eligible target population. [pmid: 16937072].
3371 Wollin J, Bennie M, Leech C, et al. Multiple sclerosis and continence issues: an exploratory study. Br J Nurs. Apr 28–May 11. 2005;14(8):439-40. 42. 44. 6. Not eligible target population. [pmid: 15924024].
3372 Wolters M, Methfessel HD, Goepel C, et al. Computer-assisted virtual urethral pressure profile in the assessment of female genuine stress incontinence. Obstetrics and gynecology. 2002:69-74. Not eligible outcomes. [pmid: 11777513].
3373 Wong L. Incontinence has different meanings for different people. Aust J Adv Nurs. Spring. 1995;13(1):6-15. Not eligible outcomes. [pmid: 7546464].
3374 Wong T, Lau BY, Mak HL, et al. Changing prevalence and knowledge of urinary incontinence among Hong Kong Chinese women. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2006;17(6):593-7. Not eligible exposure. [pmid: 16525759].
3375 Woodman PJ, Misko CA, Fischer JR. The use of short-form quality of life questionnaires to measure the impact of imipramine on women with urge incontinence. Int Urogynecol J Pelvic Floor Dysfunct. 2001;12(5):312-5. discussion 5–6. Not eligible exposure. [pmid: 11715997].
3376 Wren PA, Janz NK, Brubaker L, et al. Reliability of health-related quality-of-life measures 1 year after surgical procedures for pelvic floor disorders. Am J Obstet Gynecol. Mar. 2005;192(3):780-8. Not eligible exposure. [pmid: 15746672].
3377 Wren PA, Janz NK, FitzGerald MP, et al. Optimism in women undergoing abdominal sacrocolpopexy for pelvic organ prolapse. J Am Coll Surg. Aug. 2008;207(2):240-5. Not eligible exposure. [pmid: 18656053].
3378 Wright J. Developing a tool to assess person-centred continence care. Nurs Older People. Jul. 2006;18(6):23-8. Comment. [pmid: 16878809].
3379 Wright JL, Nathens AB, Rivara FP, et al. Specific fracture configurations predict sexual and excretory dysfunction in men and women 1 year after pelvic fracture. J Urol. Oct. 2006;176(4 Pt 1):1540-5. discussion 5. Not eligible target population. [pmid: 16952678].
3380 Wright K. Special update on incontinence in the adult. J Enterostomal Ther. Mar–Apr. 1991;18(2):26A-7A. Comment. [pmid: 1990035].
3381 Wu JM, Siddiqui NY, Amundsen CL, et al. Cost-effectiveness of botulinum toxin a versus anticholinergic medications for idiopathic urge incontinence. J Urol. May. 2009;181(5):2181-6. Secondary data analysis. [pmid: 19296983].
3382 Wu JM, Visco AG, Weidner AC, et al. Is Burch colposuspension ever cost-effective compared with tension-free vaginal tape for stress incontinence?. Am J Obstet Gynecol. Jul. 2007;197(1):62 e1-5. Not eligible exposure. [pmid: 17618760].
3383 Wu MP, Huang KH, Long CY, et al. The distribution of different surgical types for female stress urinary incontinence among patients’ age, surgeons’ specialties and hospital accreditations in Taiwan: a descriptive 10-year nationwide study. Int Urogynecol J Pelvic Floor Dysfunct. Dec. 2008;19(12):1639-46. Not eligible exposure. [pmid: 18696003].
3384 Wyllie MG. Stress incontinence: help at hand. BJU Int. May. 2004;93(7):1105-6. Comment. [pmid: 15142172].
3385 Wyllie MG. The brain leads the way. BJU Int. Nov. 2004;94(7):1137-8. Comment. [pmid: 15541141].
3386 Wyman JF. The psychiatric and emotional impact of female pelvic floor dysfunction. Curr Opin Obstet Gynecol. Aug. 1994;6(4):336-9. Not eligible exposure. [pmid: 7742497].
3387 Wyman JF, Fantl JA. Bladder training in ambulatory care management of urinary incontinence. Urol Nurs. Sep. 1991;11(3):11-7. comment. [pmid: 1925666].
3388 Xie Z, Shi H, Zhou C, et al. Alterations of estrogen receptor-alpha and -beta in the anterior vaginal wall of women with urinary incontinence. Eur J Obstet Gynecol Reprod Biol. Oct. 2007;134(2):254-8. Not eligible outcomes. [pmid: 17287066].
3389 Yalcin I, Viktrup L. Comparison of physician and patient assessments of incontinence severity and improvement. Int Urogynecol J Pelvic Floor Dysfunct. Nov. 2007;18(11):1291-5. Not eligible exposure. [pmid: 17333436].
3390 Yalcin OT, Hassa H, Ozalp S, et al. Results of the anti-incontinence operations and Kegel exercises in patients with type II anatomic stress incontinence. Acta Obstet Gynecol Scand. Mar. 1998;77(3):341-6. Not eligible exposure. [pmid: 9539284].
3391 Yamada M, Tanaka K, Yamaguchi O, et al. A new portable measuring cup for voided volume. Int J Urol. Jul. 2001;8(7):350-2. no associative hypothesis tested. [pmid: 11442655].
3392 Yamamoto M, Hibi H, Miyake K. A comparison of transurethral resection of the prostate and medical treatment for the patient with moderate symptoms of benign prostatic hyperplasia. Nagoya J Med Sci. Mar. 1996;59(1–2):11-6. Not eligible target population. [pmid: 8725483].
3393 Yamashita M, Amagai M. Family caregiving in dementia in Japan. Appl Nurs Res. Nov. 2008;21(4):227-31. Not eligible target population. [pmid: 18995165].
3394 Yang SC, Park DS, Lee JM, et al. Laparoscopic extraperitoneal bladder neck suspension (LEBNS) for stress urinary incontinence. J Korean Med Sci. Dec. 1995;10(6):426-30. Not eligible exposure. [pmid: 8924227].
3395 Yang SH, Yang JM, Wang KH, et al. Biologic correlates of sexual function in women with stress urinary incontinence. J Sex Med. Dec. 2008;5(12):2871-9. Not eligible exposure. [pmid: 18778309].
3396 Yang SS, Wang CC, Chen YT. Effectiveness of alpha1-adrenergic blockers in boys with low urinary flow rate and urinary incontinence. J Formos Med Assoc. Aug. 2003;102(8):551-5. Not eligible target population. [pmid: 14569320].
3397 Yaycioglu O, Guvel S, Gul U, et al. Does the Urodynamic Evaluation Change the Treatment Decision for Uncomplicated Female Urinary Incontinence?. Paper presented at: 21st Annual Congress of the European Association of Urology (EAU 2006). Palais des Congres, Paris (France). 5–8 Apr 2006. Not eligible outcomes.
3398 Yip SK, Chan A, Pang S, et al. The impact of urodynamic stress incontinence and detrusor overactivity on marital relationship and sexual function. Am J Obstet Gynecol. May. 2003;188(5):1244-8. Not eligible exposure. [pmid: 12748492].
3399 Yip SK, Chung TK. Treatment-seeking behavior in Hong Kong Chinese women with urinary symptoms. Int Urogynecol J Pelvic Floor Dysfunct. Feb. 2003;14(1):27-30. discussion 12601513. Not eligible target population. [pmid: 12601513].
3400 Yokoyama E. Contigen Bard Collagen implant: the Japanese experience. Int J Urol. Apr. 1995;2(Suppl 1):11-5. discussion 6–8. Not eligible exposure. [pmid: 7614409].
3401 Yokoyama O, Yusup A, Miwa Y, et al. Effects of tolterodine on an overactive bladder depend on suppression of C-fiber bladder afferent activity in rats. J Urol. Nov. 2005;174(5):2032-6. Not eligible target population. [pmid: 16217388].
3402 Yokoyama T, Fujita O, Nishiguchi J, et al. Extracorporeal magnetic innervation treatment for urinary incontinence. Int J Urol. Aug. 2004;11(8):602-6. Level of evidence. [pmid: 15285749].
3403 Yokoyama T, Inoue M, Fujita O, et al. Preliminary results of the effect of extracorporeal magnetic stimulation on urinary incontinence after radical prostatectomy: a pilot study. Urol Int. 2005;74(3):224-8. Not eligible target population. [pmid: 15812208].
3404 Yokoyama T, Nishiguchi J, Watanabe T, et al. Comparative study of effects of extracorporeal magnetic innervation versus electrical stimulation for urinary incontinence after radical prostatectomy. Urology. Feb. 2004;63(2):264-7. Not eligible target population. [pmid: 14972468].
3405 Yokoyama T, Nozaki K, Fujita O, et al. Role of C afferent fibers and monitoring of intravesical resiniferatoxin therapy for patients with idiopathic detrusor overactivity. J Urol. Aug. 2004;172(2):596-600. Not eligible exposure. [pmid: 15247740].
3406 Yong C. Effect of food on the pharmacokinetics of Oxybutynin in normal subjects. Pharm Res. 1991;8(Suppl):S-320. Not eligible target population.
3407 Yono M, Yoshida M, Takahashi W, et al. Comparison of the effects of novel antimuscarinic drugs on human detrusor smooth muscle. BJU Int. Oct. 2000;86(6):719-25. Not eligible target population. [pmid: 11069384].
3408 Yoo ES, Kim HT, Choi JD, et al. Comparison of the Two different Approaches for the Treatment of Stress Urinary Incontinence. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Not eligible exposure.
3409 Youdim K, Kogan BA. Preliminary study of the safety and efficacy of extended-release oxybutynin in children. Urology. Mar. 2002;59(3):428-32. Not eligible target population. [pmid: 11880086].
3410 Young AE, Fine PM, McCrery R, et al. Spanish language translation of pelvic floor disorders instruments. Int Urogynecol J Pelvic Floor Dysfunct. Oct. 2007;18(10):1171-8. Not eligible exposure. [pmid: 17576498].
3411 Young MD, Weizer AZ, Silverstein AD, et al. Urinary continence and quality of life in the first year after radical perineal prostatectomy. J Urol. Dec. 2003;170(6 Pt 1):2374-8. Not eligible target population. [pmid: 14634420].
3412 Young SB, Howard AE, Baker SP. Mersilene mesh sling: short- and long-term clinical and urodynamic outcomes. Am J Obstet Gynecol. Jul. 2001;185(1):32-40. Not eligible exposure. [pmid: 11483900].
3413 Youssef AHA, Fathalla M, Taema K, et al. Perineal Dermal Dartos Pedicled Flap (PDDP) a Novel Surgical Technique for Treatment of Post Prostatectomy Urinary Incontinence, Short Term Results. Paper presented at: 2007 Annual Meeting of the American Urological Association (AUA 2007). Anaheim, California (USA). 19–24 May 2007. Not eligible target population.
3414 Yu HJ, Wong WY, Chen J, et al. Quality of life impact and treatment seeking of Chinese women with urinary incontinence. Qual Life Res. May. 2003;12(3):327-33. Not eligible outcomes. [pmid: 12769145].
3415 Yu LC, Johnson K, Kaltreider DL, et al. Urinary incontinence: nursing home staff reaction toward residents. J Gerontol Nurs. Nov. 1991;17(11):34-41. Not eligible target population. [pmid: 1940115].
3416 Yu LC, Rohner TJ, Kaltreider DL, et al. Profile of urinary incontinent elderly in long-term care institutions. J Am Geriatr Soc. Apr. 1990;38(4):433-9. Not eligible target population. [pmid: 2109766].
3417 Yucel S, Akkaya E, Guntekin E, et al. Can alpha-blocker therapy be an alternative to biofeedback for dysfunctional voiding and urinary retention? A prospective study. J Urol. Oct. 2005;174(4 Pt 2):1612-5. discussion 5. Not eligible target population. [pmid: 16148665].
3418 Yucel S, Akkaya E, Guntekin E, et al. Should we switch over to tolterodine in every child with non-neurogenic daytime urinary incontinence in whom oxybutynin failed?. Urology. Feb. 2005;65(2):369-73. Not eligible target population. [pmid: 15708055].
3419 Zaccardi JE, Wilson L, Mokrzycki ML. The effect of pelvic floor re-education on comfort in women having surgery for stress urinary incontinence. Urol Nurs. Mar–Apr. 2010;30(2):137-46. 48. Not eligible target population. [pmid: 20469573].
3420 Zafar SN, Ganatra HA, Tehseen S, et al. Health and needs assessment of geriatric patients: results of a survey at a teaching hospital in Karachi. J Pak Med Assoc. Oct. 2006;56(10):470-4. Not eligible target population. [pmid: 17144398].
3421 Zahariou A, Papaioannou P, Kalogirou G. Is HCl duloxetine effective in the management of urinary stress incontinence after radical prostatectomy?. Urol Int. 2006;77(1):9-12. Not eligible target population. [pmid: 16825808].
3422 Zambroski CH, Moser DK, Roser LP, et al. Patients with heart failure who die in hospice. Am Heart J. Mar. 2005;149(3):558-64. Not eligible target population. [pmid: 15864247].
3423 Zat’ura F, Vsetica J, Abadias M, et al. Cizolirtine citrate is safe and effective for treating urinary incontinence secondary to overactive bladder: a phase 2 proof-of-concept study. Eur Urol. Jan. 2010;57(1):145-52. Not eligible exposure. [pmid: 19446951].
3424 Zehrer CL, Lutz JB, Hedblom EC, et al. A comparison of cost and efficacy of three incontinence skin barrier products. Ostomy Wound Manage. Dec. 2004;50(12):51-8. Not eligible target population. [pmid: 15632456].
3425 Zehrer CL, Newman DK, Grove GL, et al. Assessment of diaper-clogging potential of petrolatum moisture barriers. Ostomy Wound Manage. Dec. 2005;51(12):54-8. Not eligible target population. [pmid: 16439811].
3426 Zeiger B. The scope of my scope of practice. Ostomy Wound Manage. May. 2006;52(5):30-2. Comment. [pmid: 16773752].
3427 Zhang AY, Strauss GJ, Siminoff LA. Intervention of urinary incontinence and quality of life outcome in prostate cancer patients. J Psychosoc Oncol. 2006;24(2):17-30. Not eligible target population. [pmid: 17046804].
3428 Zhang AY, Strauss GJ, Siminoff LA. Effects of combined pelvic floor muscle exercise and a support group on urinary incontinence and quality of life of postprostatectomy patients. Oncol Nurs Forum. Jan. 2007;34(1):47-53. Not eligible target population. [pmid: 17562632].
3429 Zhao YD. Sample size estimation for the van Elteren test--a stratified Wilcoxon-Mann-Whitney test. Stat Med. Aug. 15. 2006;25(15):2675-87. Not eligible outcomes. [pmid: 16372389].
3430 Zhao YD, Qu Y, Rahardja D. Power approximation for the van Elteren test based on location-scale family of distributions. J Biopharm Stat. 2006;16(6):803-15. Not eligible outcomes. [pmid: 17146980].
3431 Zhu L, Lang J, Feng R, et al. Estrogen receptor in pelvic floor tissues in patients with stress urinary incontinence. Int Urogynecol J Pelvic Floor Dysfunct. Sep–Oct. 2004;15(5):340-3. Not eligible outcome. [pmid: 15580421].
3432 Zhu L, Lang J, Hai N, et al. Comparing vaginal tape and transobturator tape for the treatment of mild and moderate stress incontinence. Int J Gynaecol Obstet. Oct. 2007;99(1):14-7. Not eligible exposure. [pmid: 17707822].
3433 Zhu L, Lang J, Wang H, et al. The prevalence of and potential risk factors for female urinary incontinence in Beijing, China. Menopause. May–Jun. 2008;15(3):566-9. Not eligible outcomes. [pmid: 18467955].
3434 Zietman AL, Sacco D, Skowronski U, et al. Organ conservation in invasive bladder cancer by transurethral resection, chemotherapy and radiation: results of a urodynamic and quality of life study on long-term survivors. J Urol. Nov. 2003;170(5):1772-6. Not eligible target population. [pmid: 14532773].
3435 Zinkgraf K, Quinn AO, Ketterhagen D, et al. Percutaneous tibial nerve stimulation for treatment of overactive bladder and urinary retention in an elderly population. Urol Nurs. Jan–Feb. 2009;29(1):30-4. Comment. [pmid: 19331273].
3436 Zinner N. Long-term efficacy with continued trospium chloride use. Paper presented at: AUGS. 2004. San Diego. Level of evidence.
3437 Zorzos I, Paterson PJ. Quality of life after a Marshall-Marchetti-Krantz procedure for stress urinary incontinence. J Urol. Jan. 1996;155(1):259-62. Not eligible exposure. [pmid: 7490849].
3438 Zulkowski K, Kindsfater D. Examination of care-planning needs for elderly newly admitted to an acute care setting. Ostomy Wound Manage. Jan. 2000;46(1):32-8. Not eligible target population. [pmid: 10732634].
3439 Zullo F, Morelli M, Russo T, et al. Two techniques of laparoscopic retropubic urethropexy. J Am Assoc Gynecol Laparosc. May. 2002;9(2):178-81. Not eligible exposure. [pmid: 11960044].
3440 Zullo F, Palomba S, Piccione F, et al. Laparoscopic Burch colposuspension: a randomized controlled trial comparing two transperitoneal surgical techniques. Obstet Gynecol. Nov. 2001;98(5 Pt 1):783-8. Not eligible exposure. [pmid: 11704169].
3441 Zullo F, Palomba S, Russo T, et al. Laparoscopic colposuspension using sutures or prolene meshes: a 3-year follow-up. Eur J Obstet Gynecol Reprod Biol. Dec. 1. 2004;117(2):201-3. Not eligible exposure. [pmid: 15541858].
3442 Zullo MA, Plotti F, Calcagno M, et al. One-year follow-up of tension-free vaginal tape (TVT) and trans-obturator suburethral tape from inside to outside (TVT-O) for surgical treatment of female stress urinary incontinence: a prospective randomised trial. Eur Urol. May. 2007;51(5):1376-82. discussion 83–4. Not eligible exposure. [pmid: 17110021].
3443 Zwergel U, Wullich B, Lindenmeir U, et al. Long-term results following transurethral resection of the prostate. Eur Urol. 1998;33(5):476-80. Not eligible target population. [pmid: 9643667].
3444 Apostolidis A, Popat R, Yiangou Y, et al. Decreased sensory receptors P2X3 and TRPV1 in suburothelial nerve fibers following intradetrusor injections of botulinum toxin for human detrusor overactivity. J Urol. Sep. 2005;174(3):977-82. discussion 82–3. Not eligible outcomes. [pmid: 16094018].
3445 Doroshyenko O, Jetter A, Odenthal KP, et al. Clinical pharmacokinetics of trospium chloride. Clin Pharmacokinet. 2005;44(7):701-20. Not eligible outcomes. [pmid: 15966754].
3446 Hubner WA, Schlarp OM. Adjustable continence therapy (ProACT): evolution of the surgical technique and comparison of the original 50 patients with the most recent 50 patients at a single centre. Eur Urol. Sep. 2007;52(3):680-6. Not eligible target population. [pmid: 17097218].
3447 Karakiewicz PI, Bhojani N, Neugut A, et al. The effect of comorbidity and socioeconomic status on sexual and urinary function and on general health-related quality of life in men treated with radical prostatectomy for localized prostate cancer. J Sex Med. Apr. 2008;5(4):919-27. Not eligible target population. [pmid: 18371045].
3448 Kerbusch T, Wahlby U, Milligan PA, et al. Population pharmacokinetic modelling of darifenacin and its hydroxylated metabolite using pooled data, incorporating saturable first-pass metabolism, CYP2D6 genotype and formulation-dependent bioavailability. Br J Clin Pharmacol. Dec. 2003;56(6):639-52. Not eligible outcomes. [pmid: 14616424].
3449 Litman HJ, Steers WD, Wei JT, et al. Relationship of lifestyle and clinical factors to lower urinary tract symptoms: results from Boston Area Community Health survey. Urology. Nov. 2007;70(5):916-21. Not eligible outcomes. [pmid: 17919693].
3450 Bradley CS, Rahn DD, Nygaard IE, et al. The questionnaire for urinary incontinence diagnosis (QUID): validity and responsiveness to change in women undergoing non-surgical therapies for treatment of stress predominant urinary incontinence. Neurourol Urodyn. Jun. 2010;29(5):727-34. No associative hypothesis tested. [pmid: 19787711].
3451 Schnelle JF, Leung FW, Rao SS, et al. A controlled trial of an intervention to improve urinary and fecal incontinence and constipation. J Am Geriatr Soc. Aug. 2010;58(8):1504-11. Not eligible target population. [pmid: 20653804].
3452 Rovner ES, Wein AJ. Modern pharmacotherapy of urge urinary incontinence in the USA: tolterodine and oxybutynin. BJU Int. Oct. 2000;86(Suppl 2):44-53. discussion -4. Comment. [pmid: 11501617].