# Search Strings

April 14, 2009

Literature Strings | Result
Search (“Urinary Incontinence/radiotherapy”[Mesh] OR “Urinary Incontinence/rehabilitation”[Mesh] OR “Urinary Incontinence/surgery”[Mesh] OR “Urinary Incontinence/therapy”[Mesh]) Limits: Humans, Randomized Controlled Trial, English | 612
Search (“Urinary Incontinence/radiotherapy”[Mesh] OR “Urinary Incontinence/rehabilitation”[Mesh] OR “Urinary Incontinence/surgery”[Mesh] OR “Urinary Incontinence/therapy”[Mesh]) Limits: Humans, Journal Article, English | 9,182
Search “Epidemiologic Studies”[Mesh] AND #4 Limits: Humans, Journal Article, English | 2,367
Search “Epidemiologic Studies”[Mesh] Limits: Humans, Journal Article, English | 901,758
Search (“Urinary Incontinence/radiotherapy”[Mesh] OR “Urinary Incontinence/rehabilitation”[Mesh] OR “Urinary Incontinence/surgery”[Mesh] OR “Urinary Incontinence/therapy”[Mesh]) | 13,222

April 16, 2009

Question 1

Database: Ovid MEDLINE(R) <1950 to April Week 1 2009> Search Strategy:
>1 | exp Urinary Incontinence/di [Diagnosis] (2,523)
>2 | limit 1 to (english language and humans and (guideline or practice guideline)) (13)
>3 | exp Clinical Protocols/(91,702)
>4 | 1 and 3 (18)
>5 | exp Decision Trees/(6,776)
>6 | 1 and 5 (19)
>7 | 6 or 4 (34)
>8 | limit 7 to (English language and humans) (25)
>9 | 2 or 8 (37)

Question 3

Database: Ovid MEDLINE(R) <1950 to April Week 2 2009> Search Strategy:
>1 | exp urinary incontinence/dh, th, su, rt (9,205)
>2 | exp urinary incontinence/dt (1,539)
>3 | 1 not 2 (8,998)
>4 | (non pharmacologic or nonpharmacologic).mp. (2,448)
>5 | 1 and 4 (8)
>6 | exp treatment outcome/(383,394)
>7 | exp epidemiologic studies/ (1,103,515)
>8 | 3 or 5 (9,001)
>9 | 6 and 7 and 8 (939)
>10 | exp quality of life/ (73,696)
>11 | 7 and 8 and 10 (230)
>12 | 9 or 11 (1,032)
>13 | limit 12 to (English language and humans) (908)
>14 | limit 13 to journal article (893)

Questions 2, 5, and 9

Database: Ovid MEDLINE(R) <1950 to April Week 2 2009> Search Strategy:
>1 | exp urinary incontinence/dt (1,539)
>2 | exp treatment outcome/ (383,394)
>3 | exp quality of life/ (73,696)
>4 | 3 or 2 (444,907)
>5 | 4 and 1 (365)
>6 | exp epidemiologic studies/ (1,103,515)
>7 | 6 and 5 (96)
>8 | limit 7 to (English language and humans) (85)
>9 | limit 8 to journal article (84)

Question 4

Database: Ovid MEDLINE(R) <1950 to April Week 2 2009> Search Strategy:
>1 | exp Urinary Incontinence/dh, nu, th, su, rt, dt, rh [Diet Therapy, Nursing, Therapy, Surgery, Radiotherapy, Drug Therapy, Rehabilitation] (12,453)
>2 | exp Office Visits/ or exp Medical Office Buildings/ (4554)
>3 | exp Hospitals/ (161857)
>4 | exp Nursing Homes/ (26676)
>5 | 4 or 3 or 2 (191276)
>6 | 1 and 5 (314)
>7 | exp epidemiologic studies/ (1103515)
>8 | 6 and 7 (52)
>9 | limit 8 to (English language and humans) (48)

Question 6

Database: Ovid MEDLINE(R) <1950 to April Week 2 2009> Search Strategy:
>1 | exp urinary incontinence/ (20,881)
>2 | exp primary health care/ (55,252)
>3 | 1 and 2 (124)
>4 | exp epidemiologic studies/ (1,103,515)
>5 | 4 and 3 (16)
>6 | exp physician-patient relations/ (48,990)
>7 | 6 and 4 and 1 (12)
>8 | 7 or 5 (26)
>9 | limit 8 to English language (23)
>10 | limit 9 to journal article (22)

Question 7

Database: Ovid MEDLINE(R) <1950 to April Week 2 2009> Search Strategy:
>1 | exp Urinary Incontinence/di [Diagnosis] (2,529)
>2 | exp Diagnosis, Differential/ (316,330)
>3 | 1 and 2 (190)
>4 | limit 3 to (English language and humans) (115)

Question 8

Database: Ovid MEDLINE(R) <1950 to April Week 2 2009> Search Strategy:
>1 | exp Urinary Incontinence/th, su, dt, rh [Therapy, Surgery, Drug Therapy, Rehabilitation] (11,383)
>2 | exp Treatment Outcome/ (383,394)
>3 | 1 and 2 (2,157)
>4 | exp Evidence-Based Practice/ or exp Evidence-Based Medicine/ or evidence.mp. (756,148)
>5 | 4 and 3 (146)
>6 | limit 3 to “therapy (optimized)” (399)
>7 | 6 or 5 (502)
>8 | limit 7 to (English language and humans) (463)
>9 | exp epidemiological studies/ (1,103,515)
>10 | 8 and 9 (180)
>11 | limit 10 to journal article (177)

April 27, 2009

Literature Strings | Results
Search “Health Services Research”[Mesh] AND “Urinary incontinence” [Mesh] NOT review Limits: Humans, Journal Article, English | 137

April 20, 2009

#10 | Select 12 document(s) 17:17:22 12 #9 Search “Evidence-Based Medicine”[Mesh] Urinary incontinence Limits: Humans, English 17:03:46 124
#17 | Search “Caregivers”[Mesh] AND “Urinary Incontinence”[Mesh] NOT review Limits: Humans, Journal Article, English 17:32:56 22

May 26, 2009

Search | Literature Strings | Result
Search #6 or #7 Limits: Humans, Randomized Controlled Trial, English | | 46
Search #6 or #7 Limits: Humans, English | | 758
Search #9 and #1 and #3 Limits: Humans, Randomized Controlled Trial, English | | 402
Search #9 and #1 and #3 Limits: Humans, English | | 5,442
Search clinic or office or hospital or nursing home or longterm care, Limits: Humans, English | | 1,645,316
Search “health services research”[MeSH Terms] and urine incontinence Limits: Humans, English | | 214
Search #4 or #5 Limits: Humans, English | | 588
Search “Physician’s Practice Patterns”[MeSH Terms] and urine incontinence Limits: Humans, English | | 64
Search #1 and #2 and #3 | | 539
Search treatment or outcome | | 3,837,858
Search primary care or specialized care or urologist or urogynecologist | | 118,680
Search urine incontinence | | 18,607
Search urine incontinence and professional practice Limits: Humans, English | | 228
Stem cell AND “urinary incontinence” Limits: Humans, Journal Article, English | | 42
Estrogen AND “urinary incontinence” Limits: Humans, Journal Article, English | | 368
Adrenergic Uptake Inhibitors AND “urinary incontinence” Limits: Humans, Journal Article, English | | 162
Imipramine hydrochloride AND “urinary incontinence” Limits: Humans, Journal Article, English | | 76
Tricyclic antidepressant AND “urinary incontinence” Limits: Humans, Journal Article, English | | 81
Botulinum toxin AND “urinary incontinence” Limits: Humans, Journal Article, English | | 109
Alpha-blockers AND “Urinary Incontinence” Limits: Humans, Journal Article, English | | 101
Solifenacin AND “Urinary Incontinence” Limits: Humans, Journal Article, English | | 48
Vesicare AND “Urinary Incontinence” Limits: Humans, Journal Article, English | | 4
Enablex AND “Urinary Incontinence” Limits: Humans, Journal Article, English | | 54
Sanctura AND “Urinary Incontinence” Limits: Humans, Journal Article, English | | 3
Ditropan AND “Urinary Incontinence” Limits: Humans, Journal Article, English | | 286
Detrol AND “Urinary Incontinence” Limits: Humans, Journal Article, English | | 198
“Urinary Incontinence” Limits: Humans, Randomized Controlled Trial, English | | 789
(“Urinary Incontinence/radiotherapy”[Mesh] OR “Urinary Incontinence/rehabilitation”[Mesh] OR “Urinary Incontinence/surgery”[Mesh] OR “Urinary Incontinence/therapy”[Mesh]) Limits: Humans, Randomized Controlled Trial, English | | 621
(“Urinary Incontinence/radiotherapy”[Mesh] OR “Urinary Incontinence/rehabilitation”[Mesh] OR “Urinary Incontinence/surgery”[Mesh] OR “Urinary Incontinence/therapy”[Mesh]) | | 13,302
“Caregivers”[Mesh] AND “Urinary Incontinence” Limits: Humans, Journal Article, English | | 40
“Physician-Patient Relations” [Mesh] AND “Urinary incontinence” | | 48
“Delivery of Health Care”[Mesh] AND “Urinary incontinence” Limits: Humans, Journal Article, English | | 1,438
“Health services re”[MeSH] AND “Urinary incontinence” Limits: Humans, Journal Article, English | | 186
“Physician’s Practice Patterns”[MeSH] AND “Urinary incontinence” Limits: Humans, Journal Article, English | | 57
“Quality of life” AND “Urinary incontinence” Limits: Humans, Journal Article, English | | 1,689
“Urinary Incontinence/diagnosis”[Mesh] Limits: Humans, Randomized Controlled Trial, English | | 83
“Urinary Incontinence/diagnosis”[Mesh] Limits: Humans, Journal Article, English | | 2,328
“Epidemiologic Studies”[Mesh] AND “Urinary Incontinence/diagnosis”[Mesh] Limits: Humans, Randomized Controlled Trial, Controlled Clinical Trial, Multicenter Study, Validation Studies, English | | 66
“Urinary Incontinence” AND urologist Limits: Humans, Journal Article, English | | 78
“Urinary Incontinence” AND urogynecologist Limits: Humans, Journal Article, English | | 7
“Urinary Incontinence” AND gynecologist Limits: Humans, Journal Article, English | | 29

June 26, 2009

Search (Urinary incontinence) AND systematic[sb] | 581
Search diary AND “urinary incontinence” AND sensitivity Limits: Humans, English | 20

July 20, 2009

Cochrane RCT database

Urinary incontinence and Women | 457
Urinary incontinence NOT surgery | 138

Updated search August 20, 2009

Search (“Urinary Incontinence/diagnosis”[Mesh] OR “Urinary Incontinence/diet therapy”[Mesh] OR “Urinary Incontinence/drug therapy”[Mesh] OR “Urinary Incontinence/therapy”[Mesh]) Limits: published in the last 180 days, Humans, Journal Article, English, All Adult: 19+ years | 86

October 13, 2009

Search “Duloxetine Urinary Incontinence Study Group”[Corporate Author] | 4

Updated search November 10, 2009

Search ((“Urinary incontinence”[Text Word]) AND (“2009/04/01”[Publication Date] : “3000”[Publication Date])) AND (Urinary incontinence) Limits: Randomized Controlled Trial English | 33

March 25, 2010

Search tolterodine Limits: Randomized Controlled Trial (“2009/04/01”[Publication Date] : “3000”[Publication Date])) AND (Urinary incontinence) Limits: Randomized Controlled Trial, English | 134
Search fesoterodine | 48
Search Solifenacin | 194

March 30, 2011

“urinary incontinence” OR “overactive bladder” OR fesoterodine OR oxybutynin OR trospium OR solifenacin OR tolterodine Limits: Female, Randomized Controlled Trial, English, All Adult: 19+ years | 865

Grey Literature search using key words “Urinary incontinence” on July 27, 2010

Regulatory Information FDA Health Canada Authorized Medicines for EU Clinical Trial Registries ClinicalTrials.gov - 120 Search for UI among all close studies: additional -100 records Australian New Zealand Clinical Trials Registry (ANZCTR) - 1 Clinical Study Results - 4 WHO Clinical Trials - 18 Clinical Trials Registry - India (CTRI) - 1 Japanese Registry of clinical trials (JPRN) - 4 Netherlands Trial Register - 6 Abstracts and Conference Papers Conference Papers Index - 318 Scopus - 243 International Continence Society and the International Urogynecological Association – 2010 meeting | Grants and Federally Funded Research NIH RePORTER (a searchable database of federally funded biomedical research projects conducted at universities, hospitals, and other research institutions)- 487

September 2010

“Urinary incontinence” OR “overactive bladder” OR fesoterodine OR oxybutynin OR trospium OR solifenacin OR tolterodine Limits: Female, Randomized Controlled Trial, English, All Adult: 19+ years | 794
“Urinary incontinence” Limits: Humans, Journal Article, English, All Adult: 19+ years, Publication Date from 2009/01/01 to 2010/12/31 | 903

Additional searches recommended by the peer reviewers

Contigen “urinary incontinence” Limits: Humans, Randomized Controlled Trial, Multicenter Study, English | 10
Search “transcutaneous tibial nerve stimulation” AND “urinary incontinence” NOT review Limits: Humans, English | 11
Search “tibial nerve stimulation” AND “urinary incontinence” NOT review Limits: Humans, English | 16

Continuously updated search

November 2011- updated searches
“Urinary incontinence” OR “overactive bladder” OR fesoterodine OR oxybutynin OR trospium OR solifenacin OR tolterodine Limits: Humans, Randomized Controlled Trial, English, published in the last 3 years | 267

December 2011

Search “urinary incontinence” OR “overactive bladder” OR fesoterodine OR oxybutynin OR trospium OR solifenacin OR tolterodine Limits: Female, Randomized Controlled Trial, English, All Adult: 19+ years | 893

Database: Ovid MEDLINE(R) 1950 to December 2011 Search Strategy:

1 | exp Urinary Incontinence/di [Diagnosis] (2,849)
2 | exp Diagnosis, Differential/ (347,297)
3 | 1 and 2 (201)
4 | limit 3 to (English language and humans) (120)

Database: Ovid MEDLINE(R) 1950 to December 2011 Search Strategy:

1 | exp urinary incontinence/dt (1,728)
2 | exp treatment outcome/ (517,761)
3 | exp quality of life/ (94,744)
4 | 3 or 2 (595309)
5 | 4 and 1 (447)
6 | exp epidemiologic studies/ (1359275)
7 | 6 and 5 (116)
8 | limit 7 to (English language and humans) (103)

Table A1 Results of the request for Scientific Information Packets (SIP) by the Scientific Resource Center

Company | SIP Letter Sent | SIP Received
Abbott Laboratories | 8/13/2010 | [no SIP]
Accelerated Care Plus | 8/13/2010 | [no SIP]
ACP - Accelerated Care Plus Corporation | 8/13/2010 | [no SIP]
Actavis US | 8/13/2010 | [no SIP]
AL Voss Associates | 8/13/2010 | [no SIP]
Allergan, Inc. | 8/13/2010 | [no SIP]
Astellas Pharmaceuticals | 8/13/2010 | [no SIP]
AstraZeneca Pharmaceuticals, LP | 8/13/2010 | [no SIP]
Bioness, Inc. | 8/13/2010 | [no SIP]
BIOTEQUE AMERICA, INC. | 8/13/2010 | [no SIP]
Bristol-Myers Squibb | 8/13/2010 | [no SIP]
Duramed Subsidiary of Barr Pharmaceuticals | 8/13/2010 | [no SIP]
Eli Lilly & Co | 8/13/2010 | [no SIP]
Hollister Incorporated | 8/13/2010 | [no SIP]
Impax Laboratories, Inc. | 8/13/2010 | [no SIP]
Ivax Pharmaceuticals (Teva Pharmaceuticals) | 8/13/2010 | [no SIP]
Laborie Medical Technologies | 8/13/2010 | [no SIP]
Mentor Corp | 8/13/2010 | [no SIP]
Mikart | 8/13/2010 | [no SIP]
Mutual Pharma (URL Pharma Inc) | 8/13/2010 | [no SIP]
Mylan Pharmaceuticals | 8/13/2010 | [no SIP]
New River Pharmaceuticals | 8/13/2010 | [no SIP]
Nexstim Inc | 8/13/2010 | [no SIP]
Novartis Pharmaceuticals Corporation | 8/13/2010 | [no SIP]
Novavax Inc. | 8/13/2010 | [no SIP]
Nycomed US Inc | 8/13/2010 | [no SIP]
Odyssey Pharmaceuticals, Inc | 8/13/2010 | [no SIP]
Ortho-McNeil Janssen Scientific Affairs, LLC | 8/13/2010 | 8/31/2010
Osmotica Pharmaceutical Corp | 8/13/2010 | [no SIP]
Pfizer Inc | 8/13/2010 | [no SIP]
Purepac Pharmaceuticals | 8/13/2010 | [no SIP]
Ranbaxy | 8/13/2010 | [no SIP]
Reliant Technologies, Inc. | 8/13/2010 | [no SIP]
Roche Laboratories | 8/13/2010 | [no SIP]
Rochester Medical Corporation | 8/13/2010 | 9/10/2010
Roxane | 8/13/2010 | [no SIP]
Sandoz Inc | 8/13/2010 | [no SIP]
Sanofi Aventis US | 8/13/2010 | [8/27/2010 nothing to supply]
Schering-Plough Corporation | 8/13/2010 | [no SIP]
Silarx Pharmaceuticals, Inc. | 8/13/2010 | [no SIP]
Somaxon Pharmaceuticals | 8/13/2010 | [no SIP]
Taro Pharmaceuticals | 8/13/2010 | [no SIP]
Teva Pharmaceuticals USA | 8/13/2010 | [no SIP]
UCB, Inc | 8/13/2010 | [no SIP]
USL Pharmaceuticals | 8/13/2010 | [no SIP]
Vanguard Pharma | 8/13/2010 | [no SIP]
Warner Chilcott Company, Inc. | 8/13/2010 | [no SIP]
Wockhardt | 8/13/2010 | [no SIP]
Wyeth Pharmaceuticals Headquarters | 8/13/2010 | [no SIP]
PLIVA HRVATSKA DOO | 8/13/2010 | [no SIP]
Tyco Healthcare UK Commercial Ltd. | 8/13/2010 | [no SIP]