# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project. We would like to thank the librarians, Judy Stanke, M.A., and Delbert Reed, Ph.D., for their contributions to the literature search; Rema Ramakrishnan, M.P.H., and Shiyi Wang, M.D., for their assistance with the literature search and data abstraction; Jeannine Ouellette for her help in writing the report; Marilyn Eells for editing and formatting the report; and Nancy Russell, M.L.S., Yaminah Oliver, Christa Prodzinski, and Michele Rockne for assistance with data entry, quality control, and formatting tables. We would like to thank Dr. Trikalinos, M.D., Ph.D., and Dr. Rücker, PhD., for their statistical help in arcsine transformation of the data.