# Abbreviations

AHRQ: Agency for Healthcare Research and Quality
ARD: Absolute risk difference
BMI: Body Mass Index
CI: Confidence interval
ER: Extended release
FDA: Food and Drug Administration
ICI: International Consultation on Incontinence
ICS: International Continence Society
I-QOL: Incontinence Quality of Life
IUGA: International Urologynecological Association
MeSH: Medical Subject Headings
NNT: Number needed to treat
OAB: Overactive bladder
OPERA: Overactive bladder: Performance of Extended Release Agents
PFMT: Pelvic floor muscle training
PVR: Post-void residual
RCTs: Randomized controlled trials
RR: Relative risk
SRC: Scientific Resource Center
UDI: Urogenital Distress Inventory
UI: Urinary incontinence