# Technical Expert Panel

Jeff Andrews, M.D., FRCSC, FACOG

Associate Professor

Vanderbilt University Medical Center

Nashville, TN

Jeanne-Marie Guise, M.D., M.P.H.

Department of Obstetrics and Gynecology

Oregon Health and Science University

Portland, OR

Sylvia Lopez, M.D.

Oklahoma Health Care Authority

Oklahoma City, OK

James Reichmann, M.B.A.

American Homepatient Inc.

Brentwood, TN

Fung Lam, M.D.

Comprehensive Center for Pelvic Medicine

California-Pacific Medical Center

San Francisco, California