# Results

## Literature Search

The PRISMA diagram in Figure 2 depicts the flow of retrieved records through the phases of screening and inclusion. The titles and/or abstracts of 427 citations were screened at Level 1. These citations were identified from database searching, reference lists, grey literature, and Technical Expert Panel nomination. We did not identify any relevant data in the Scientific Information Packets submitted by pharmaceutical industries.

Figure 2 PRISMA diagram

FDA = U.S. Food and Drug Administration; SQ = subcutaneous; TEP = Technical Expert Panel

Figure 2 is a flow chart that summarizes the number of citations identified, screened, excluded, and included. There were 426 citations identified from electronic databases, grey literature, reference lists, and nominations from TEP members. Four of these records were unavailable, so 422 citations were screened at Level 1. Of these, 210 citations were excluded and 212 passed on to Level 2 (full-text) screening. A total of 197 full-text articles were excluded for the following reasons: subcutaneous terbutaline pump was not given as maintenance tocolytic therapy in at least one group; citation was a review article, letter to editor, commentary, FDA warning, or newspaper article; study of maternal or neonatal outcomes or harms with no comparison group (this reason included studies where women served as their own controls); case reports; abstract or full-text not in English; full-text unavailable; did not include women with arrested preterm labor; did not assess one of the outcomes; companion article with no additional data; study design did not allow for an evaluation of subcutaneous terbutaline pump as the sole maintenance tocolytic therapy; and other miscellaneous reasons, such as absence of patient data. Fifteen records were included in the review. Fourteen were independent studies and one was an informative companion article.

At full-text screening, 212 records were reviewed. Most records (n=197) were excluded with reasons listed in the PRISMA diagram. Ultimately, 14 unique records comprised the evidence base to answer the key questions. One record was an informative companion article for the study by Allbert et al. (1994).20,44 A list of excluded studies is provided in Appendix E.

### General Study Characteristics

Most studies were observational in design and all were from the United States. Participants were recruited from single center study sites (n=9)10-14,20-23 or from a national proprietary database run by Matria (now called Alere) Healthcare, which provides an outpatient perinatal program consisting of 24-hour nursing and pharmacy support, home uterine activity monitoring, individualized education, and provision of tocolytic therapy to women with preterm labor (n=5).15-19 The comparison groups were placebo (saline pump),10,11 no treatment,13 oral terbutaline,11,12,20,21 oral nifedipine,15-17 and oral tocolytics.14,18,19 The definition of labor was unclear in 36 percent of the included studies. The remaining studies included women with persistent contractions and cervical change.

### Population

All studies included women who had at least one episode of preterm labor that was arrested with primary tocolytic treatment (often with parenteral magnesium sulfate) with subsequent placement on a maintenance tocolytic regimen. Nine of 14 studies reported persistent contractions or contractions > 4 per hour accompanied by cervical changes as their definition of labor (Appendix F, Table F1). In several studies, only women with two or more episodes of preterm labor during the same pregnancy (i.e., recurrent preterm labor) were eligible for inclusion.13-20,23 Several studies were conducted exclusively in women with singleton gestation,10,12,13,15,17,18 although a few studies evaluated women with twins only.16,19 Some studies may have included women less than 24 weeks' gestational age (an inclusion criterion for the review was 24–36 weeks plus 6 weeks), but data for these participants could not be separated.10,15-20,22

No studies presented data on concomitant medications, body mass index (BMI), history of preeclampsia, cervical position, cervical consistency, cervical station, Bishop's Score, or fetal fibronectin. Table 2 presents other maternal characteristics that were reported in the studies.

Table 2 Maternal characteristics

Characteristic | Number of Studies That Reported Characteristic | Value
Mean maternal age | 12^10-16,18-22^ | 21.6–32.4 years
Mean GA at preterm labor | 6^13,15-19^ | 29.5–31.6 weeks
Mean GA at start of therapy | 6^10-12,20,22,23^ | 29.1–32.2 weeks
Race | 5^10,13,19-21,*^ | European (white); Hispanic; African; Asian; Other (“nonwhite”)
Comorbidities | 2^13,22^ | Bacterial vaginosis; asthma; urinary tract infection; fibroids; chronic hypertension/pregnancy induced hypertension; HELLP syndrome
History of preterm birth | 7^10,13,16-19,22^ | 10.8–75%
Cerclage | 6^15-19,22^ | 2.8–13.1%
Gravidity | 2^11,18^ | 2.6 (mean)18 2.25, 2.5, 2.6 (medians)11
Parity | 3^11,14,20^ | 1.2 (mean),20 1.4 (mean)14 0.5, 0.5, 0.7 (medians)11
Membrane status | 8^10,13-16,20,22,23^ | Intact
Mean cervical length | 1^23^ | 0.2 cm
Mean cervical dilation | 5^10,11,13,20,23^ | 1.7–2.9 cm
Cervical effacement | 1^10^ | 50% (median)

GA = gestational age; HELLP syndrome = hemolysis, elevated liver function values, low platelet count

* None of these studies reported separate effect estimates for different races.

### Intervention

At least one group was administered subcutaneous terbutaline (SQ terbutaline) infusion by pump for maintenance tocolysis in all studies. The basal infusion rate was 0.05 to 0.086 mg/h.10,18-20,23 In several studies, the basal infusion was individualized based on uterine activity pattern, subjective symptoms, BMI, and/or other pharmacokinetic parameters.12,13,15-17,19,22 The mean bolus dose was 0.24 to 0.30 mg.10-13,15,18,19,22,23 Most studies provided some details about pump training, such as instruction on self-management, site selection and care, syringe change, administration of additional bolus doses, and/or heart rate monitoring.10,13,15-20,22,23

No study reported data on dose of primary tocolytic agents, compliance with pump protocol, or brand name of terbutaline. Other intervention characteristics are presented below in Table 3.

Table 3 Intervention characteristics

Characteristic | Number of Studies That Reported Characteristic | Value
Primary tocolytic agent | 6^10-13,22,23^ | Magnesium sulfate (IV); indomethacin (PO, PR); terbutaline (SQ injections); ritodrine (IV); nifedipine (PO)
Corticosteroid use during acute tocolysis | 1^11^ | IM betamethasone
Mean number of boluses per day | 5^11,18-20,23^ | 5.4 - 8
Mean terbutaline dose per day | 4^17-19,21^ | 2.5 - 3.9 mg
Pump type | 6^10,12,18,19,22,23^ | AS6-C U300; microinfusion pump; model 404-S; model 404-SP
Pump manufacturer | 10^10-14,17-19,22,23^ | Autosyringe, Travenol; Minimed Technologies; Disetronics

IM = intramuscular; IV = intravenous; PO = oral; PR = rectal; SQ = subcutaneous

### Double-counting of Outcomes Data

Five studies originated in the Matria database, and not all reported geographic region and/or years over which participants were recruited. Therefore, the question of overlap in participants across these studies was an important concern of reviewers. Through the Scientific Resource Center, we requested this missing information from Matria (now called Alere) Healthcare but did not receive a response. Hence, where appropriate, we report this risk of double-counting of participants.

Participants may have been double-counted among the following sets of Matria-based studies:

- Flick et al. and Fleming et al. both selected women with singleton gestation who were prescribed oral nifedipine as a comparator and Lam et al. (2003) selected women with singleton gestation prescribed oral tocolytics as a comparator. Participants may have been double-counted in both SQ terbutaline pump and comparator groups in the studies by Flick et al. and Fleming et al.16,17 Double-counting of participants in the comparator group between Flick et al. or Fleming et al. and the latter third study is expected to be minimal because 95.3 percent in the comparator group of Lam et al. were taking oral terbutaline.18 However, there is a possibility that the SQ terbutaline pump sample of participants overlapped in all three studies.
- de la Torre et al. and Lam et al. (2001) selected women with twin gestation and used oral nifedipine or oral tocolytics as comparators respectively.16,19 Double-counting of participants in the comparator groups will be minimal because 92.3 percent of participants in the oral tocolytic group of the study by Lam et al. (2001) were administered oral terbutaline.19 However, there is still a possibility that participants in the SQ terbutaline pump groups of these two studies overlapped.

### Risk of Bias Assessment

Figures 3, 4, 5, and 6 present risk of bias charts for cohorts, case series, nonrandomized trials, and randomized controlled trials (RCTs) respectively. The bars in black represent studies with risk of bias, and the bars in grey represent studies without risk of bias for the corresponding criteria. Studies that were rated as unclear are represented by white bars. Table F2 in Appendix F presents the full text question that was posed for the criteria listed in the charts. The overall ratings for risk of bias of individual studies are presented in the evidence table (Table F1, Appendix F). Table F3 in Appendix F presents detailed risk of bias assessments for each study.

Figure 5 Risk of bias assessment for nonrandomized trials (n=1)

Figure 5 is a bar chart depicting risk of bias assessments for the single nonrandomized trial in the review. The chart shows individual risk of bias criteria and overall study risk of bias. Treatment and comparison groups were derived from different sample populations; methods to control for confounders were inappropriate; patients, healthcare providers, and outcome assessors were not blinded to treatment allocation and healthcare providers were not blinded to maternal contractions. The overall risk of bias for the outcomes of birthweight and gestational age at delivery was high. The overall risk of bias for the outcome of hyperglycemia was medium.

Figure 6 Risk of bias assessment for RCTs (n=3, randomized arms)

Figure 6 is a bar chart depicting risk of bias assessments for the three randomized arms, which came from two randomized trials, in the review. The chart shows individual risk of bias criteria and overall study risk of bias. Subjects were not representative of the source population in two randomized arms; blinding of patients, healthcare providers, and outcome assessors was inadequate in two arms; sample size was too small in two arms; one randomized trial may be biased due to source of funding; in two randomized arms the primary outcome was not defined, harm-related outcomes were not pre-specified, collection of harm outcomes was not specified as active, and the training or background of personnel collecting harms data was not reported. The overall risk of bias was high for two randomized arms and medium for one randomized arm.

Figure 7 Mean gestational age (in weeks) at delivery (RCT pooled estimate: I^2^ = 0.0 percent, p-value>0.05)

RCT = randomized controlled trial; SQ = subcutaneous

*Discrepancies were found in the information presented in the text and table of this paper. Mean gestational age at delivery for SQ terbutaline pump was reported as 36.6 weeks in table and 37.2 weeks in text. The value 36.6 weeks was used to calculate difference in means.

Figure 7 displays the effect estimates for mean gestational age at delivery in a forest plot. Observational studies tended to show statistically significant differences, in favor of subcutaneous terbutaline pump. Randomized controlled trials showed nonsignificant differences (pooled estimate from RCTs: I2=0.00 and p-value > 0.05).

Figure 8 Incidence of delivery < 32 weeks' gestation

SQ = subcutaneous

Figure 8 displays the effect estimates for incidence of delivery < 32 weeks in a forest plot. Observational studies showed statistically significant differences, in favor of subcutaneous terbutaline pump.

We rated studies as high risk of bias if we could identify at least one major flaw with the potential to significantly bias results. If we could not assess several factors due to incomplete information, but there was no major flaw, then we rated studies as medium risk of bias. We provided a rating of low risk of bias only if there were no identifiable flaws and there was sufficient information to evaluate most criteria.

### Cohort Studies (n=9)

We rated five cohort studies as high risk of bias 13-15,18,21 and four as medium risk of bias (Figure 3).16,17,19,20 The cohort studies with high risk of bias all had imbalances in baseline characteristics or prognostic factors. We rated the remaining cohort studies as medium risk of bias because we could not assess several criteria due to incomplete reporting.

Figure 3 Risk of bias assessment for cohort studies

Figure 3 is a bar chart depicting risk of bias assessments for the nine cohort studies in the review. The chart shows individual risk of bias criteria and overall study risk of bias. Five cohort studies had group imbalances in baseline characteristics or prognostic factors; in one cohort study treatment and comparison groups did not receive the same primary tocolytic agent; in two cohort studies treatment and comparison groups received different levels of care; in one cohort study the sample population from which the comparison group was derived was not the same as the sample population of the treatment group; six cohort studies did not use appropriate methods to control for confounders; one cohort study clearly did not conduct an intention-to-treat analysis; there was selective outcome reporting in one cohort study; the primary outcome was not pre-specified in four cohort studies; and the mode of harms collection was not specified as active in one cohort study. The overall risk of bias was high for five cohort studies and medium for four cohort studies.

### Case Series (n=2)

We rated both case series as medium risk of bias (Figure 4).22,23 Although we could not identify any major methodological flaws, neither study provided clear definitions for the pump-related harm outcomes. Several criteria, such as compliance, adequacy of sample size, and selective outcome reporting, were unclear.

Figure 4 Risk of bias assessment for case series (n=2)

Figure 4 is a bar chart depicting risk of bias assessments for the two case series in the review. The chart shows individual risk of bias criteria and overall study risk of bias. One case series may have been biased due to funding source. In none of the case series were primary or harm-related outcomes pre-specified. Also, the collection of harm-related outcomes was not specified and the training or background of personnel collecting harms data was not reported in both case series. The overall risk of bias for the two case series was medium.

### Nonrandomized Comparative Trials (n=1)

We rated the single nonrandomized trial as having high risk of bias for the outcomes birthweight and gestational age at delivery, and medium risk of bias for the outcome maternal hyperglycemia (Figure 5).12 Allocation to intervention or comparator groups was based on primary tocolytic treatment. Participants who received < 24 hours of primary tocolysis were placed on oral terbutaline and participants who received > 24 hours of primary tocolysis, multiple courses of tocolysis, or multiple agents, were placed on terbutaline pump. This allocation scheme may have created prognostic differences among groups, which may have had an impact on the preterm birth outcomes (i.e., birth weight and gestational age at delivery). However, there is no clear indication that this would impact the outcome of maternal hyperglycemia.

### RCTs (n=3, Randomized Arms)

Figure 6 presents risk of bias assessments for RCTs.10,11 One RCT had two comparators (placebo and oral terbutaline), and we assessed each randomized arm separately.11 We rated both arms as high risk of bias because the study was likely underpowered, blinding was ineffective, and the participants who participated in the study represented a select group of patients because more than 90 percent of eligible participants declined to participate.11 We rated the second RCT as low risk of bias because randomization was carried out properly and patients and health care providers were blinded.10

### Sources of Funding

Most studies did not report sources of funding (Table 4). One RCT 10 and one case series 22 were industry funded.

Table 4 Sources of funding

Reference | Source
Flick (2010)15 | Not reported
de la Torre (2008)16 | Not reported
Fleming (2004)17 | Not reported
Lam (2003)18 | Not reported
Morrison (2003)13 | Not reported
Lam (2001)19 | Not reported
Guinn (1998)10 | MiniMed Technologies (supported in part)
Wenstrom (1997)11 | Not reported
Allbert (1994)20 | Vicksburg Hospital Medical Foundation (supported in part)
Adkins (1993)22 | PharmaThera Inc.
Regenstein (1993)21 | National Institutes of Health Training
Lindenbaum (1992)12 | Not reported
Morrison (1992)14 | Vicksburg Hospital Medical Foundation (supported in part)
Lam (1988)23 | Not reported

## Key Question 1 Neonatal Health Outcomes

In women with arrested preterm labor, does treatment with a SQ infusion of terbutaline delivered by a pump, in comparison with placebo, conservative treatment or other interventions, improve neonatal health outcomes, including bronchopulmonary dysplasia, neonatal death, death within initial hospitalization, significant intraventricular hemorrhage (grade III/IV), necrotizing enterocolitis, periventricular leukomalacia, retinopathy of prematurity, seizures, sepsis, and stillbirth for the following subgroups:

a. Women <28 weeks, 0 days of gestation (extremely preterm)?
b. Women between 28 weeks, 0 days of gestation and 31 weeks, 6 days of gestation (very preterm)?
c. Women between 32 weeks, 0 days of gestation and 33 weeks, 6 days of gestation (preterm)?
d. Women between 34 weeks, 0 days of gestation and 36 weeks, 6 days of gestation (later preterm)?
e. Multiple gestation?
f. Racial or ethnic subgroups?
g. Women with previous preterm birth?
h. Women with history of preeclampsia?
i. Women with recurrent preterm labor (RPTL) and women without RPTL?

### Key Points

- Strength of evidence was graded as insufficient for the outcomes of bronchopulmonary dysplasia, death within initial hospitalization, and significant intraventricular hemorrhage (grade III/IV) and for all populations of interest.
- For neonatal death, strength of evidence favoring SQ terbutaline pump over oral tocolytics is low for women with twin gestation and RPTL. For other populations, the evidence was graded as insufficient.
- Underpowered studies demonstrated indeterminate results for the outcomes of necrotizing enterocolitis, retinopathy of prematurity, sepsis, and stillbirth (i.e., type II error cannot be excluded).
- No data were available for periventricular leukomalacia and seizures.
- Data were unavailable for subgroups a–d and for subgroups f–h.

### Detailed Analysis

Table F4 in Appendix F presents data for Key Question 1. None of the included studies reported data on bronchopulmonary dysplasia (strength of evidence is insufficient), death within initial hospitalization (strength of evidence is insufficient), periventricular leukomalacia, and seizures. Data could not be separated for women of specific gestational ages (subgroups a–d), racial or ethnic subgroups (subgroup f), women with previous preterm birth (subgroup g), and women with history of preeclampsia (subgroup h).

Below we report results by outcome, grade strength of evidence (for the following prespecified outcomes that were reported in studies: significant intraventricular hemorrhage and neonatal death), and summarize determinants of applicability where relevant. Results from Matria-based studies pertained to women who were inducted into a U.S. national database and who received specialized services from an outpatient perinatal program. We graded the strength of evidence for the specific populations of interest, as indicated in the key question. We also graded evidence from two RCTs that pertained to a nonspecific population of women with preterm labor; one RCT was in women with singleton gestation 10 and the other RCT was in women with either single or twin gestation (effect estimates were not presented separately by gestation).11

Summary tables are presented if more than one study was available for an outcome, otherwise all information has been summarized in the text.

#### Neonatal Death

Neonatal death was reported in three studies. Heterogeneity in study design, patient population, and comparator groups precluded evidence synthesis (Table 5). Either no or a sparse number of events were reported in all studies for followup to delivery.

Table 5 Summary table for neonatal death

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Retrospective cohort (2) | Women with singleton gestation and RPTL from the Matria database (n=284)17 | Oral nifedipine | Medium | No neonatal deaths were observed in two of the three studies.11,17 One retrospective cohort of women with twin gestation and RPTL demonstrated a statistically significant difference in neonatal death, with fewer events in the SQ terbutaline pump group (OR=0.09, 95% CI: 0.01, 0.70).
Retrospective cohort (2) | Women with twin gestation and RPTL from the Matria database (n=706)19 | Oral tocolytics (92.3% received oral terbutaline) | Medium
RCT (1) | Women with single or twin gestation from the University of Iowa Hospital (n=42)11 | Placebo and oral terbutaline | High

CI = confidence interval; OR = odds ratio; RCT = randomized controlled trial; RPTL = recurrent preterm labor; SQ = subcutaneous

In a retrospective cohort of women with singleton gestation and RPTL, no neonatal deaths were reported among the SQ terbutaline pump group or oral nifedipine comparator group.17 Similarly, no neonatal deaths occurred in an RCT of women with singleton or twin gestation who received SQ terbutaline pump or placebo.11 However, in a retrospective cohort of women with twin gestation and RPTL from the Matria database, Lam et al. demonstrated a statistically significant difference between SQ terbutaline pump and oral tocolytics, with fewer neonatal deaths occurring in the SQ terbutaline pump group (odds ratio [OR] = 0.09, 95% confidence interval [CI]: 0.01, 0.70).19

The overall strength of evidence in favor of SQ terbutaline pump for neonatal death was graded as low for twin gestation (subgroup e) and RPTL (subgroup i), based on the study by Lam et al. (Table 6).19 Strength of evidence for all other populations was insufficient. Strength of evidence for neonatal death for a nonspecific preterm labor population described in an RCT is insufficient (Table 7).11

Table 6 Neonatal death – Strength of evidence for populations of interest

Population | Number of Studies | Number of Participants | Number of Events | Strength of Evidence Domain: Risk of Bias | Strength of Evidence Domain: Consistency | Strength of Evidence Domain: Directness | Strength of Evidence Domain: Precision | OR (95% CI) | Strength of Evidence
Twin gestation + RPTL COHORT: SQ terbutaline pump vs. oral tocolytics19 | 1 | 706 | 12 | Medium | N/A | Direct | Precise | 0.09 (0.01, 0.70) | Low
Singleton gestation + RPTL COHORT: SQ terbutaline pump vs. oral nifedipine17 | 1 | 284 | 0 | Medium | N/A | Direct | Imprecise | 1.00 (0.02, 50.75) | Insufficient

CI = confidence interval; OR = odds ratio; RPTL = recurrent preterm labor; SQ = subcutaneous

Table 7 Neonatal death – Strength of evidence for nonspecific preterm labor populations

Population | Number of Studies | Number of Participants | Number of Events | Strength of Evidence Domain: Risk of Bias | Strength of Evidence Domain: Consistency | Strength of Evidence Domain: Directness | Strength of Evidence Domain: Precision | OR (95% CI) | Strength of Evidence
Singleton or twin gestation RCT: SQ terbutaline pump vs. placebo11 | 1 | 27 | 0 | High | N/A | Direct | Imprecise | 0.79 (0.01, 42.38) | Insufficient
Singleton or twin gestation RCT: SQ terbutaline pump vs. oral terbutaline11 | 1 | 30 | 0 | High | N/A | Direct | Imprecise | 0.85 (0.02, 45.00) | Insufficient

CI = confidence interval; OR = odds ratio; RCT = randomized controlled trial; SQ = subcutaneous

#### Significant Intraventricular Hemorrhage (Grade III/IV)

Two studies reported data on significant intraventricular hemorrhage (grade III/IV) (Table 8). These studies were not synthesized because of heterogeneous study designs, patient populations, and comparators. Both studies were underpowered to detect a difference due to sparse event rates and small sample sizes.

Table 8 Summary table for significant intraventricular hemorrhage (grade III/IV)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Prospective cohort (1) | Women with singleton gestation and RPTL (n=60)13 | No treatment | High | No events were observed in the RCT. A statistically nonsignficant difference was observed in the prospective cohort (OR=0.30, 95% CI: 0.02, 5.85).
RCT (1) | Women with singleton gestation from Birmingham Hospital (n=52)10 | Placebo | Low | No events were observed in the RCT. A statistically nonsignficant difference was observed in the prospective cohort (OR=0.30, 95% CI: 0.02, 5.85).

CI = confidence interval; OR = odds ratio; RCT = randomized controlled trial; RPTL = recurrent preterm labor

Morrison et al. compared SQ terbutaline pump with no treatment in a prospective cohort of women with singleton gestation and RPTL.13 This study reported a nonsignificant difference (OR = 0.30, 95% CI: 0.02, 5.85).13 In the second study, which did not pertain to any of the populations of interest, women with singleton gestation were randomly allocated to receive either SQ terbutaline pump or placebo; significant intraventricular hemorrhage was not observed in either group.10

We graded the overall strength of evidence as insufficient for women with RPTL (subgroup i) based on the prospective cohort study (Table 9). Strength of evidence for all other populations of interest was insufficient because no studies were available. Based on the RCT in a nonspecific preterm labor population, strength of evidence is insufficient (Table 10).10

Table 9 Significant intraventricular hemorrhage (grade III/IV) – Strength of evidence for populations of interest

Population | Number of Studies | Number of Participants | Number of Events | Strength of Evidence Domain: Risk of Bias | Strength of Evidence Domain: Consistency | Strength of Evidence Domain: Directness | Strength of Evidence Domain: Precision | OR (95% CI) | Strength of Evidence
Singleton gestation + RPTL COHORT: SQ terbutaline pump vs. no treatment13 | 1 | 60 | 4 | High | N/A | Direct | Imprecise | 0.30 (0.02, 5.85) | Insufficient

CI = confidence interval; OR = odds ratio; RPTL = recurrent preterm labor; SQ = subcutaneous

Table 10 Significant intraventricular hemorrhage (grade III/IV) – Strength of evidence for nonspecific preterm labor populations

Population | Number of Studies | Number of Participants | Number of Events | Strength of Evidence Domain: Risk of Bias | Strength of Evidence Domain: Consistency | Strength of Evidence Domain: Directness | Strength of Evidence Domain: Precision | OR (95% CI) | Strength of Evidence
Singleton gestation RCT: SQ terbutaline pump vs. placebo10 | 1 | 52 | 0 | Low | N/A | Direct | Imprecise | 1.21 (0.02, 63.48) | Insufficient

CI = confidence interval; OR = odds ratio; RCT = randomized controlled trial; SQ = subcutaneous

#### Necrotizing Enterocolitis

Necrotizing enterocolitis was reported in a single prospective cohort that compared the SQ terbutaline pump with no treatment in women with singleton gestation and RPTL.13 One case was reported in the no treatment comparator group, which resulted in a nonsignificant effect estimate (OR=0.96, 95% CI: 0.04, 24.74).13 Given that there was only one event among a sample size of 60 participants, this study was clearly underpowered to detect a difference in this outcome. We rated this study as high risk of bias because intervention and comparator groups were imbalanced in risk factors for preterm birth, primary tocolytic therapy, and level of care.

#### Retinopathy of Prematurity and Sepsis

Retinopathy of prematurity and sepsis were reported in a single RCT of women with singleton or twin gestation who presented to a university hospital.11 This study did not address any of the subgroups of interest. One infant in the SQ terbutaline pump group developed retinopathy of prematurity, and one infant in the oral terbutaline group developed sepsis.11 Although both results were statistically nonsignificant, this study was underpowered to detect differences in either outcome. This study was rated as high risk of bias because of selection bias, limitations in study power, and absence of blinded outcome assessment.

#### Stillbirth

Three retrospective cohort studies reported data on stillbirth (Table 11).17-19 These studies could not be meta-analyzed because sample populations and comparators were diverse and differences in confounders could not be excluded.

Table 11 Summary table for stillbirth

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Retrospective cohort (3) | Women with singleton gestation and RPTL from the Matria database (n=284)17 | Oral nifedipine | Medium | All studies found statistically nonsignificant differences between SQ terbutaline pump and comparators. (OR=2.01, 95% CI: 0.18, 22.47; OR=3.01, 95% CI: 0.12, 74.23; OR=0.75, 95% CI: 0.17, 3.36). Participants in the SQ terbutaline pump groups of the singleton studies may have been double-counted.
Retrospective cohort (3) | Women with singleton gestation and RPTL from the Matria database (n=558)18 | Oral tocolytics (95.3% received oral terbutaline) | High
Retrospective cohort (3) | Women with twin gestation and RPTL from the Matria database (n=706)19 | Oral tocolytics (92.3% received oral terbutaline) | Medium

CI = confidence interval; OR = odds ratio; RPTL = recurrent preterm labor; SQ = subcutaneous

All three studies indicated statistically nonsignificant differences in the occurrence of stillbirth between the SQ terbutaline pump group and oral nifedipine or oral tocolytic comparator groups. Two of these studies were exclusively in women with singleton gestation 17,18 and one restricted to twins.19 All studies were underpowered to detect a difference in this outcome because of low event rates (total number of events ranged from one to seven). Furthermore, there is potential for participant overlap among the SQ terbutaline pump groups of the two singleton studies.17,18

## Key Question 2 Other Surrogate Outcomes

In women with arrested preterm labor, does treatment with a SQ infusion of terbutaline delivered by a pump, in comparison with placebo, conservative treatment or other interventions improve other surrogate outcomes, including mean gestational age at delivery, incidence of delivery at various gestational ages (<28 weeks, < 32 weeks, < 34 weeks, < 37 weeks), mean prolongation of pregnancy (days), birth weight, ratio of birth weight/gestational age at delivery, mean pregnancy prolongation index, need for assisted ventilation, need for oxygen per nasal cannula, and neonatal intensive care unit (NICU) admission, for the following subgroups:

a. Women <28 weeks, 0 days of gestation (extremely preterm)?
b. Women between 28 weeks, 0 days of gestation and 31 weeks, 6 days of gestation (very preterm)?
c. Women between 32 weeks, 0 days of gestation and 33 weeks, 6 days of gestation (preterm)?
d. Women between 34 weeks, 0 days of gestation and 36 weeks, 6 days of gestation (later preterm)?
e. Multiple gestation?
f. Racial or ethnic subgroups?
g. Women with previous preterm birth?
h. Women with history of preeclampsia?
i. Women with RPTL and women without RPTL?

### Key Points

No data were available for the following outcomes: incidence of delivery < 28 weeks (strength of evidence is insufficient), need for oxygen per nasal cannula, or ratio of birth weight/gestational age at delivery.

#### Mean Gestational age at Delivery

##### Multiple Gestation

Two cohorts of medium risk of bias from the Matria database reported statistically significant differences in favor of the SQ terbutaline pump, compared with oral tocolytics. The risk of double-counting of participants could not be ruled out.

##### RPTL

Six cohorts of medium to high risk of bias, mostly from the Matria database, reported statistically significant differences in favor of SQ terbutaline pump compared with oral tocolytics or no treatment. Again, there is risk of double-counting of participants across these studies.

##### Overall Evidence

Two RCTs and two observational studies, which did not pertain to any population of interest, reported statistically nonsignificant differences between SQ terbutaline pump and placebo or oral tocolytics. This evidence contrasted with results from larger cohort studies, which demonstrated consistent benefit. The RCTs and other observational studies, which showed nonsignificant differences, may have been underpowered.

#### Incidence of Delivery at Various Gestational Ages

##### < 32 weeks

Strength of evidence favoring SQ terbutaline pump compared with oral tocolytics or no treatment for women with twin gestation or RPTL is low. This evidence came mostly from Matria-based studies.

##### < 34 weeks

Strength of evidence is insufficient for all populations of interest. One RCT of medium risk of bias, which did not pertain to any population of interest, reported a statistically nonsignificant difference compared with placebo, although type II error cannot be excluded.

##### < 37 weeks

Strength of evidence favoring SQ terbutaline pump compared with oral tocolytics or no treatment is insufficient or low for women with RPTL. This evidence came mostly from Matria-based studies.

#### Prolongation of Pregnancy

Strength of evidence favoring the SQ terbutaline pump compared with oral tocolytics or no treatment for women with twin gestation or RPTL was graded as insufficient or low for mean prolongation of pregnancy. This evidence came mostly from Matria-based studies.

Two retrospective cohorts of medium and high risk of bias, from the Matria database, reported pregnancy prolongation > 7 days in women with RPTL. One cohort reported a statistically significant difference in favor of the SQ terbutaline pump, compared with oral tocolytics. The other reported a nonsignificant difference, although type II error cannot be excluded.

Five retrospective cohorts of medium to high risk of bias, from the Matria database, reported pregnancy prolongation > 14 days in women with RPTL and single or twin gestation. All reported statistically significant differences in favor of SQ terbutaline pump, compared with oral tocolytics. Overlap in the study sample between these studies cannot be ruled out.

#### Mean Birth Weight

##### Multiple Gestation

Two cohorts of medium risk of bias from the Matria database reported statistically significant differences in favor of SQ terbutaline pump, compared with oral tocolytics. Overlap in the study sample between the two studies cannot be ruled out.

##### RPTL

Five of six cohorts, mostly from the Matria database and of medium to high risk of bias, reported statistically significant differences in favor of SQ terbutaline pump compared with oral tocolytics or no treatment. Overlap in the study sample between the Matria-based studies cannot be ruled out.

##### Overall evidence

Two RCTs, which did not pertain to any population of interest, reported statistically nonsignificant differences between SQ terbutaline pump and placebo. This result is indeterminate because of possible type II error. The RCT evidence contrasted with results from larger cohort studies, which demonstrated consistent benefit.

#### Incidence of low Birth Weight

##### Multiple Gestation

Two cohorts of medium risk of bias from the Matria database reported statistically significant differences in favor of SQ terbutaline pump, compared with oral tocolytics. Overlap in the study sample between the two studies cannot be ruled out.

##### RPTL

Six cohorts, mostly from the Matria database and of medium to high risk of bias, reported statistically significant differences in favor of SQ terbutaline pump compared with oral tocolytics or no treatment. Study sample may have overlapped among the Matria-based studies.

#### Incidence of Very low Birth Weight

##### Multiple Gestation

Two cohorts of medium risk of bias from the Matria database reported statistically significant differences in favor of SQ terbutaline pump, compared with oral tocolytics. Overlap in the study sample between the two studies cannot be ruled out.

##### RPTL

Three of four cohorts of medium to high risk of bias, from the Matria database, reported statistically significant differences in favor of SQ terbutaline pump compared with oral tocolytics. The study sample may have overlapped.

#### Pregnancy Prolongation Index

Two cohorts of medium and high risk of bias in women with RPTL reported statistically significant differences in favor of SQ terbutaline pump, compared with oral terbutaline or no treatment.

#### Need for Assisted Ventilation

One retrospective cohort of high risk of bias in women with singleton gestation and RPTL from the Matria database reported a nonsignificant difference in need for ventilator among infants with NICU admission.

#### Incidence of NICU Admission

##### Multiple Gestation

Two cohorts of medium risk of bias from the Matria database reported statistically significant differences in favor of SQ terbutaline pump, compared with oral tocolytics. Overlap in the study sample between the two studies cannot be ruled out.

##### RPTL

Six cohorts of medium to high risk of bias, mostly from the Matria database, reported statistically significant differences in favor of SQ terbutaline pump, compared with oral tocolytics or no treatment. Participant overlap among Matria-based studies cannot be ruled out.

#### NICU Mean Length of Stay

##### Multiple Gestation

One retrospective cohort of medium risk of bias, in women with twin gestation from the Matria database, reported a statistically significant difference in favor of SQ terbutaline pump compared with oral tocolytics.

##### RPTL

Four retrospective cohorts, mostly from the Matria database and primarily of high risk of bias, reported statistically significant differences in favor of SQ terbutaline pump, compared with oral tocolytics or no treatment. Participant overlap among Matria-based studies cannot be ruled out.

### Detailed Analysis

Tables F5 to F9 in Appendix F present data extracted for Key Question 2. No data were available for incidence of delivery < 28 weeks (strength of evidence is insufficient), need for oxygen per nasal cannula, or ratio of birthweight/gestational age at delivery. Information was unavailable for women of specific gestational ages (subgroups a–d), racial or ethnic subgroups (subgroup f), women with previous preterm birth (subgroup g), or women with history of preeclampsia (subgroup h).

Results are presented below by outcome, along with strength of evidence grades for certain prespecified outcomes (i.e., incidence of delivery at various gestational ages and mean prolongation of pregnancy) and determinants of applicability. We graded the strength of evidence for the specific populations of interest, as indicated in the key question. We also graded evidence from two RCTs that pertained to a nonspecific population of women with preterm labor; one RCT was in women with singleton gestation10 and the other RCT was in women with either single or twin gestation (effect estimates were not presented separately by gestation).11

If a single study was available on an outcome, then all information has been summarized in the text. Otherwise, we have summarized information in tables for each outcome according to the populations of interest. When we had information that did not pertain to any of the specific populations, we also summarized the population-specific and nonspecific data (which we have termed overall evidence) in tables and/or forest plots. We have presented forest plots to display the entire body of evidence for outcomes that had data from several studies.

The results from Matria-based studies pertained to women who were inducted into a U.S. national database and who received specialized services from an outpatient perinatal program. There is risk of double-counting of participants across some of the Matria-based studies.

#### Mean Gestational age at Delivery

Table F5 in Appendix F presents study-level data for mean gestational age at delivery. Eleven heterogeneous studies reported gestational age at delivery. Two were RCTs,10,11 one was a nonrandomized trial,12 two were prospective cohorts,13,14 and the remaining were retrospective cohorts.15-19,21 Comparator groups included placebo,10,11 no treatment,13 and various oral tocolytic agents.12,14-19,21 Data were available for women with twin gestation (subgroup e)16,19 and women with RPTL (subgroup i)13,15-19 The other studies did not explicitly address any of the populations of interest.10-12,14,21

##### Subgroup: Multiple Gestation

Two retrospective cohorts that used the Matria database were exclusively in women with twin gestation (Table 12).16,19 Both studies demonstrated statistically significant differences in gestational age at delivery, with greater mean gestational age among women who received SQ terbutaline pump (difference in means = 0.70 weeks, 95% CI: 0.43 weeks, 0.97 weeks and 0.70 weeks, 95% CI: 0.48 weeks, 0.92 weeks).16,19 Both studies were rated as medium risk of bias because several criteria, such as similarity in baseline characteristics and prognostic factors, could not be assessed due to incomplete reporting.

Table 12 Summary table for mean gestational age at delivery (subgroup: multiple gestation)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Retrospective cohort (2) | Women with twin gestation and RPTL from the Matria database (n=656,)16 | Oral nifedipine | Medium | Both studies demonstrated statistically significant differences in favor of SQ terbutaline pump.16,19 Participants in the SQ terbutaline pump groups may have overlapped.
Retrospective cohort (2) | Women with twin gestation and RPTL from the Matria database (n=706)19 | Oral tocolytics (92.3% received oral terbutaline) | Medium | Both studies demonstrated statistically significant differences in favor of SQ terbutaline pump.16,19 Participants in the SQ terbutaline pump groups may have overlapped.

RPTL = recurrent preterm labor ; SQ = subcutaneous

##### Subgroup: RPTL

One prospective cohort13 and five retrospective cohorts specified RPTL as an inclusion criterion (Table 13).15-19 Two of these studies were also in women with twin gestation, as described above.16,19 The remaining four studies were in women with singleton gestation.

Table 13 Summary table for mean gestational age at delivery (subgroup: RPTL)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Prospective cohort (1) | Women with singleton gestation and RPTL (n=60)13 | No treatment | High | All studies demonstrated statistically significant differences, in favor of SQ terbutaline pump. The possibility of participant overlap among the two Matria-based twin studies and among the three Matria-based singleton studies cannot be ruled out.
Retrospective cohort (5) | Women with singleton gestation and RPTL from the Matria database (n=1366)15 | Oral nifedipine | High
Retrospective cohort (5) | Women with singleton gestation and RPTL from the Matria database (n=284) 17 | Oral nifedipine | Medium
Retrospective cohort (5) | Women with singleton gestation and RPTL from the Matria database (n=558)18 | Oral tocolytics (95.3% received oral terbutaline) | High
Retrospective cohort (5) | Women with twin gestation and RPTL from the Matria database (n=656)16 | Oral nifedipine | Medium
Retrospective cohort (5) | Women with twin gestation and RPTL from the Matria database (n=706)19 | Oral tocolytics (92.3% received oral terbutaline) | Medium

RPTL = recurrent preterm labor ; SQ = subcutaneous

The prospective cohort reported a statistically significant difference in gestational age at delivery between the SQ terbutaline pump and no treatment, in favor of the pump (difference in means = 3.40 weeks, 95% CI: 1.80 weeks, 5.00 weeks).13 However, this study was rated as high risk of bias because the groups were imbalanced in preterm birth risk factors, primary tocolytic therapy, and level of care. This study included women with singleton gestation only, the majority of whom were of African American origin.

All retrospective cohorts used the Matria database and reported statistically significant differences in favor of SQ terbutaline pump, compared with oral tocolytics (difference in means range = 0.70-0.90 weeks, 95% CI range: 0.28-0.48 weeks, 0.92-1.52 weeks).15-19 Two studies were rated as high risk of bias because of group imbalances15,18 and three were rated as medium risk of bias because the information presented in the reports was insufficient to assess several criteria, such as group comparability.16,17,19

##### Overall Evidence

Irrespective of patient populations and comparators, a total of 11 studies contributed evidence to the outcome of gestational age at delivery (Table 14). When compared with placebo, the RCT evidence for SQ terbutaline pump was indeterminate, given the small sample size (Figure 7).10,11 Five larger observational cohort studies that used the Matria database and that were of medium to high risk of bias, showed consistent benefit with the pump in comparison with other tocolytics.15-19

Table 14 Summary table for mean gestational age at delivery (overall evidence)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
RCT (2) | Women with singleton gestation from Birmingham Hospital (n=52)10 | Placebo | Low | A pooled estimate of the placebo arms of the two RCTs was nonsignificant. This result is indeterminate, given the small sample sizes of both studies. Five larger observational cohort studies of medium to high risk of bias showed a consistent benefit with the pump in comparison with other tocolytics.15-19 However, there is a possibility that participants overlapped among some of these studies. Other observational studies demonstrated nonsignificant differences.14,21 The possibility of type II error cannot be excluded.
RCT (2) | Women with singleton or twin gestation from the University of Iowa Hospital (n=42)11 | Placebo and oral terbutaline | High
Nonrandomized trial (1) | Women with singleton gestation from the Hospital of the University of Pennsylvania (n=91)12 | Oral terbutaline | High
Prospective cohort (2) | Women with singleton gestation and RPTL (n=60)13 | No treatment | High
Prospective cohort (2) | Likely included a mixture of women with single and multiple gestation (n=69)14 | Oral tocolytics | High
Retrospective cohort (6) | Women with singleton gestation and RPTL from the Matria database (n=1366)15 | Oral nifedipine | High
Retrospective cohort (6) | Women with singleton gestation and RPTL from the Matria database (n=284) 17 | Oral nifedipine | Medium
Retrospective cohort (6) | Women with singleton gestation and RPTL from the Matria database (n=558)18 | Oral tocolytics (95.3% received oral terbutaline) | High
Retrospective cohort (6) | Women with twin gestation and RPTL from the Matria database (n=656)16 | Oral nifedipine | Medium
Retrospective cohort (6) | Women with twin gestation and RPTL from the Matria database (n=706)19 | Oral tocolytics (92.3% received oral terbutaline) | Medium
Retrospective cohort (6) | Likely included a mixture of women with single and multiple gestation (n=69)21 | Oral terbutaline | High

RCT = randomized controlled trial; RPTL = recurrent preterm labor

#### Incidence of Delivery at Various Gestational Ages

Study-level data for incidence of delivery at various gestational ages are presented in Table F6, Appendix F.

#### Incidence of Delivery < 32 Weeks' Gestation

Six cohort studies reported incidence of delivery at gestational age < 32 weeks' gestation. Data were available for women with multiple gestation16,19 and women with RPTL.13,15-19

##### Subgroup: Multiple Gestation

Two retrospective cohorts included women with twin gestation only (Table 15). 16,19 Both studies reported a statistically significant difference in the incidence of delivery < 32 weeks, with fewer cases in the SQ terbutaline pump group compared with oral tocolytics (OR=0.47, 95% CI: 0.33, 0.68 and OR=0.52, 95% CI: 0.35, 0.76).16,19 We rated both studies as medium risk of bias because incomplete reporting precluded assessment of several criteria, such as similarity in baseline characteristics and prognostic factors.

Table 15 Summary table for incidence of delivery < 32 weeks' gestation (subgroup: multiple gestation)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Retrospective cohort (2) | Women with twin gestation and RPTL from the Matria database (n=656,)16 | Oral nifedipine | Medium | Both studies demonstrated statistically significant differences in favor of SQ terbutaline pump.16,19 Participants in the SQ terbutaline pump groups may have overlapped.
Retrospective cohort (2) | Women with twin gestation and RPTL from the Matria database (n=706)19 | Oral tocolytics (92.3% received oral terbutaline) | Medium | Both studies demonstrated statistically significant differences in favor of SQ terbutaline pump.16,19 Participants in the SQ terbutaline pump groups may have overlapped.

RPTL = recurrent preterm labor; SQ = subcutaneous

Based on these two studies, we graded the strength of evidence favoring the SQ terbutaline pump compared with oral tocolytics as low, for the population of women with twin gestation (Table 17). This evidence pertained to women with twin gestation and RPTL from the Matria database.

Table 20 Incidence of delivery < 37 weeks' gestation – Strength of evidence for populations of interest

Population | Number of Studies | Number of Participants | Number of Events | Strength of Evidence Domains: Risk of Bias | Strength of Evidence Domains: Consistency | Strength of Evidence Domains: Directness | Strength of Evidence Domains: Precision | OR (95% CI) | Strength of Evidence
Singleton Gestation + RPTL
COHORT: SQ terbutaline pump vs. oral nifedipine15,17 | 2 | 1650 | 925 | High/Medium | Consistent^*^ | Indirect | Imprecise | 0.72-0.75 (lower CI range 0.47-0.58, upper CI range 0.90-1.20) | Insufficient
COHORT: SQ terbutaline pump vs. oral tocolytics18 | 1 | 558 | 318 | High | N/A | Indirect | Precise | 0.70 (0.50, 0.98) | Low
COHORT: SQ terbutaline pump vs. no treatment13 | 1 | 60 | 50 | High | N/A | Indirect | Precise | 0.04 (0.01, 0.23) | Low
Singleton/Multiple Gestation + RPTL
COHORT: SQ terbutaline pump vs. oral terbutaline20 | 1 | 64 | 38 | Medium | N/A | Indirect | Precise | 0.10 (0.03, 0.32) | Low

CI = confidence interval; OR = odds ratio; RPTL = recurrent preterm labor; SQ = subcutaneous

* Studies were not pooled. Also, there was risk of double-counting of participants across these studies.

##### Subgroup: RPTL

The entire body of evidence for this outcome pertained to women with RPTL (Table 16 and Figure 8). Four studies were in women with singleton gestation,13,15,17,18 and two studies, which are described above, were in women with twin gestation.16,19 These studies all found statistically significant differences in favor of the SQ terbutaline pump, compared with either no treatment or oral tocolytics.13,15-19 Three studies were rated as high risk of bias due to group imbalances,13,15,18 and three studies were rated as medium risk of bias due to incomplete reporting, which precluded an assessment of group comparability.16,17,19

Table 16 Summary table for incidence of delivery < 32 weeks' gestation (subgroup: RPTL)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Prospective cohort (1) | Women with singleton gestation and RPTL (n=60)13 | No treatment | High | Multiple Gestation: Two retrospective studies in women with twins reported statistically significant differences, in favor of SQ terbutaline pump. Possibility of overlap in participants cannot be ruled out. RPTL: Entire body of evidence pertained to women with RPTL. All studies reported statistically significant differences, in favor of SQ terbutaline pump. Possibility of participant overlap among some studies cannot be ruled out.
Retrospective cohort (5) | Women with singleton gestation and RPTL from the Matria database (n=1366)15 | Oral nifedipine | High
Retrospective cohort (5) | Women with singleton gestation and RPTL from the Matria database (n=284)17 | Oral nifedipine | Medium
Retrospective cohort (5) | Women with singleton gestation and RPTL from the Matria database (n=558)18 | Oral tocolytics (95.3% received oral terbutaline) | High
Retrospective cohort (5) | Women with twin gestation and RPTL from the Matria database (n=656)16 | Oral nifedipine | Medium
Retrospective cohort (5) | Women with twin gestation and RPTL from the Matria database (n=706)19 | Oral tocolytics (or 92.3% received oral terbutaline) | Medium

RPTL = recurrent preterm labor; SQ = subcutaneous

Strength of evidence for different comparators and patient populations (i.e., singletons and twins) favoring the SQ terbutaline pump is low for women with RPTL (Table 17). Aside from the comparison against no treatment in women with singletons, the evidence for all other comparators and populations pertained to women from the Matria database. The study with the no treatment comparison group included women who were mostly of African American origin.13

Table 17 Incidence of delivery < 32 weeks' gestation – Strength of evidence for populations of interest

Population | N_studies_ | N_Participants_ | Number of Events | Strength of Evidence Domains | | | | OR (95% CI) | Strength of Evidence
Population | N_studies_ | N_Participants_ | Number of Events | Risk of Bias | Consistency | Directness | Precision | OR (95% CI) | Strength of Evidence
Twin Gestation + RPTL
COHORT: SQ terbutaline pump vs. oral nifedipine (twins)16 | 1 | 656 | 192 | Medium | N/A | Indirect | Precise | 0.47 (0.33, 0.68) | Low
COHORT: SQ terbutaline pump vs. oral tocolytics19 | 1 | 706 | 124 | Medium | N/A | Indirect | Precise | 0.52 (0.35, 0.76) | Low
Singleton Gestation + RPTL
COHORT: SQ terbutaline pump vs. oral nifedipine15,17 | 2 | 1650 | 106 | High/Medium | Consistent^*^ | Indirect | Precise | 0.20–0.29 (lower CI range 0.07-0.16, upper CI range 0.52-0.61) | Low
COHORT: SQ terbutaline pump vs. oral tocolytics 18 | 1 | 558 | 37 | High | N/A | Indirect | Precise | 0.21 (0.09, 0.50) | Low
COHORT: SQ terbutaline pump vs. no treatment 13 | 1 | 60 | 21 | High | N/A | Indirect | Precise | 0.04 (0.00, 0.65) | Low

CI = confidence interval; N/A = not applicable; OR = odds ratio; RPTL = recurrent preterm labor; SQ = subcutaneous

* Studies were not pooled. Also, there was risk of double-counting of participants across these studies.

#### Incidence of Delivery < 34 Weeks' Gestation

Strength of evidence was graded insufficient for all populations of interest. Only a single RCT, which compared the SQ terbutaline pump with placebo in women with singleton gestation, reported a nonsignificant difference in the incidence of delivery < 34 weeks (OR = 0.95, 95% CI: 0.32, 2.87).10 Based on the small sample size, the possibility of type II error cannot be excluded. The strength of evidence for this nonspecific preterm labor population is insufficient (Table 18).

Table 18 Incidence of delivery < 34 weeks' gestation – Strength of evidence for nonspecific preterm labor populations

Population | N_studies_ | N_Participants_ | Number of Events | Strength of Evidence Domains | | | | OR (95% CI) | Strength of Evidence
Population | N_studies_ | N_Participants_ | Number of Events | Risk of Bias | Consistency | Directness | Precision | OR (95% CI) | Strength of Evidence
Singleton Gestation
RCT: SQ terbutaline pump vs. placebo10 | 1 | 52 | 22 | Low | N/A | Indirect | Imprecise | 0.95 (0.32, 2.87) | Insufficient

CI = confidence interval; OR = odds ratio; RCT = randomized controlled trial; SQ = subcutaneous

#### Incidence of Delivery < 37 Weeks' Gestation

Six studies reported incidence of delivery < 37 weeks' gestation. Population-specific data were available only for women with RPTL.13,15,17,18,20 One RCT, which did not pertain to any specific population of interest, randomized women with singleton gestation to SQ terbutaline pump or placebo and reported a nonsignificant difference (OR=1.57, 95% CI: 0.49, 5.02) (Figure 9).10

Figure 9 Incidence of delivery < 37 weeks' gestation

RCT = randomized controlled trial; SQ = subcutaneous

Figure 9 displays the effect estimates for incidence of delivery < 37 weeks in a forest plot. Most observational studies showed statistically significant differences, in favor of subcutaneous terbutaline pump. One randomized controlled trial showed a nonsignificant difference.

##### Subgroup: RPTL

Four retrospective cohorts and one prospective cohort reported incidence of delivery < 37 weeks in women with RPTL (Table 19).13,15,17,18,20 Aside from one study, all included women with singleton gestation only.13,15,17,18 One study likely consisted of women with single and multiple gestation.20 Four of the five studies reported statistically significant differences in favor of SQ terbutaline pump, compared with oral tocolytics or no treatment (OR range = 0.04-0.72, 95% CI range: 0.01-0.58, 0.23-0.98).13,15,18,20 These studies were of medium to high risk of bias.

Table 19 Summary table for incidence of delivery < 37 weeks' gestation (subgroup: RPTL)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Prospective cohort (1) | Women with singleton gestation and RPTL (n=60)13 | No treatment | High | Most studies reported statistically significant differences, in favor of SQ terbutaline pump. Participants may have overlapped among some of the Matria-based studies.
Retrospective cohort (4) | Women with singleton gestation and RPTL from the Matria database (n=1366)15 | Oral nifedipine | High | Most studies reported statistically significant differences, in favor of SQ terbutaline pump. Participants may have overlapped among some of the Matria-based studies.
Retrospective cohort (4) | Women with singleton gestation and RPTL from the Matria database (n=284)17 | Oral nifedipine | Medium | Most studies reported statistically significant differences, in favor of SQ terbutaline pump. Participants may have overlapped among some of the Matria-based studies.
Retrospective cohort (4) | Women with singleton gestation and RPTL from the Matria database (n=558)18 | Oral tocolytics (95.3% received oral terbutaline) | High | Most studies reported statistically significant differences, in favor of SQ terbutaline pump. Participants may have overlapped among some of the Matria-based studies.
Retrospective cohort (4) | Women with RPTL and likely included a mixture of women with single and multiple gestation (n=64)20 | Oral terbutaline | Medium | Most studies reported statistically significant differences, in favor of SQ terbutaline pump. Participants may have overlapped among some of the Matria-based studies.

RCT = randomized controlled trial; RPTL = recurrent preterm labor; SQ = subcutaneous

Although Fleming et al. and Flick et al. both investigated women with singleton gestation from the Matria database and used the same comparator (i.e., oral nifedipine), Fleming et al. reported a nonsignificant difference (OR=0.75, 95% CI: 0.47, 1.20)17 but Flick et al. reported a significant difference in favor of SQ terbutaline pump (OR=0.72, 95% CI: 0.58, 0.90).15 The sample size in the Flick et al. study was much larger so, in the absence of any apparent clinical diversity, it appears that lower power in the Fleming et al. study may explain this difference.

For the population of women with RPTL, we graded the strength of evidence favoring SQ terbutaline pump compared with various comparators as insufficient or low (Table 20). The majority of this evidence was derived from the Matria database.15,17,18 The study with the no treatment comparator group included women who were mostly of African American origin13 and the study with oral terbutaline as a comparator group likely included women with single and multiple gestation, the majority of whom were classified as “nonwhite.”20 The strength of evidence for a nonspecific preterm labor population from the RCT is insufficient (Table 21).10

Table 21 Incidence of delivery < 37 weeks' gestation – Strength of evidence for nonspecific preterm labor populations

Population | Number of Studies | Number of Participants | Number of Events | Strength of Evidence Domains: Risk of Bias | Strength of Evidence Domains: Consistency | Strength of Evidence Domains: Directness | Strength of Evidence Domains: Precision | OR (95% CI) | Strength of Evidence
Singleton Gestation
RCT: SQ terbutaline pump vs. placebo10 | 1 | 52 | 34 | Low | N/A | Indirect | Imprecise | 1.57 (0.49, 5.02) | Insufficient

CI = confidence interval; OR = odds ratio; RCT = randomized controlled trial; SQ = subcutaneous

#### Prolongation of Pregnancy

Studies that reported prolongation of pregnancy are presented in Table F7, Appendix F. This outcome was reported either as a continuous variable (i.e., mean prolongation of pregnancy) or as a dichotomous variable (i.e., pregnancy prolongation > 7 days or > 14 days). In most studies, the prolongation of pregnancy interval was defined.10,13,15-17,19 Population-specific data were available for women with multiple gestation and women with RPTL.

#### Mean Prolongation of Pregnancy

Seven studies reported mean prolongation of pregnancy. One observational study included women with twin gestation only16 and five observational studies pertained to women with RPTL.13,15-18 Two RCTs did not pertain to any populations of interest.10,11

##### Subgroup: Multiple Gestation

One retrospective cohort compared SQ terbutaline pump with oral nifedipine in women with twin gestation and RPTL from the Matria database.16 Prolongation of pregnancy was measured from episode of RPTL to delivery. A statistically significant difference was observed in favor of the SQ terbutaline pump (difference in means in days: 7.20, 95% CI: 4.10, 10.30). We rated this study as medium risk of bias because there was insufficient information to assess several criteria, such as comparability of groups in baseline characteristics and prognostic factors.

The strength of evidence in favor of the SQ terbutaline pump compared with oral nifedipine for this specific population is low, based on this single study (Table 24).

Table 24 Mean prolongation of pregnancy – Strength of evidence for populations of interest

Population | N_studies_ | N_Participants_ | Strength of Evidence Domains | | | | MD (95% CI) (days) | Strength of Evidence
Population | N_studies_ | N_Participants_ | Risk of Bias | Consistency | Directness | Precision | MD (95% CI) (days) | Strength of Evidence
Twin Gestation + RPTL
COHORT: SQ terbutaline pump vs. oral nifedipine16 | 1 | 656 | Medium | N/A | Indirect | Precise | 7.20 (4.10, 10.30) | Low
Singleton Gestation + RPTL
COHORT: SQ terbutaline pump vs. oral nifedipine15,17 | 2 | 1650 | High/Medium | Consistent^*^ | Indirect | Imprecise | 6.20-7.50 (lower CI range 0.79-4.94, upper CI range 10.06-11.61 | Insufficient
COHORT: SQ terbutaline pump vs. oral tocolytics18 | 1 | 558 | High | N/A | Indirect | Precise | 5.50 (2.28, 8.72 | Low
COHORT: SQ terbutaline pump vs. no treatment13 | 1 | 60 | High | N/A | Indirect | Precise | 25.30 (16.77, 33.83) | Low

CI = confidence interval; MD = mean difference; RPTL = recurrent preterm labor; SQ = subcutaneous

* Studies were not pooled. Also, there was risk of double-counting of participants across these studies

##### Subgroup: RPTL

Five studies pertained to women with RPTL, including the one study in twins described above (Table 22 and Figure 10).13,15-18 Statistically significant differences were reported by all studies, compared with either oral tocolytics or no treatment (difference in means in days ranged from 5.50-25.30, 95% CI range: 0.79-16.77, 8.72-33.83).13,15-18 Three studies were rated as high risk of bias because groups were imbalanced in baseline characteristics and/or prognostic factors.13,15,18 Two studies were rated as medium risk of bias because information presented in the report was insufficient to assess several criteria, such as group comparability.16,17

Table 22 Summary table for mean prolongation of pregnancy (subgroup: RPTL)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Prospective cohort (1) | Women with singleton gestation and RPTL (n=60)13 | No treatment | High | All studies reported statistically significant differences, in favor of SQ terbutaline pump. Participants may have overlapped among some of these studies.
Retrospective cohort (4) | Women with singleton gestation and RPTL from the Matria database (n=1366)15 | Oral nifedipine | High | All studies reported statistically significant differences, in favor of SQ terbutaline pump. Participants may have overlapped among some of these studies.
Retrospective cohort (4) | Women with singleton gestation and RPTL from the Matria database (n=284)17 | Oral nifedipine | Medium | All studies reported statistically significant differences, in favor of SQ terbutaline pump. Participants may have overlapped among some of these studies.
Retrospective cohort (4) | Women with singleton gestation and RPTL from the Matria database (n=558)18 | Oral tocolytics (95.3% received oral terbutaline) | High | All studies reported statistically significant differences, in favor of SQ terbutaline pump. Participants may have overlapped among some of these studies.
Retrospective cohort (4) | Women with twin gestation and RPTL from the Matria database (n=656)16 | Oral nifedipine | Medium | All studies reported statistically significant differences, in favor of SQ terbutaline pump. Participants may have overlapped among some of these studies.

RPTL = recurrent preterm labor; SQ = subcutaneous

Figure 10 Mean prolongation of pregnancy (RCT pooled estimate: I^2^ = 0.0 percent, p-value > 0.05)

RCT = randomized controlled trial; SQ = subcutaneous

Figure 10 displays the effect estimates for mean prolongation of pregnancy in a forest plot. Observational studies showed statistically significant differences, in favor of subcutaneous terbutaline pump. Randomized controlled trials showed nonsignificant differences (pooled estimate from RCTs: I2=0.00 and p-value > 0.05).

Strength of evidence favoring SQ terbutaline pump against various comparators for the populations of women with RPTL is insufficient or low (Table 24). The majority of evidence came from the Matria-based studies.15-18 In the study with the no treatment comparison group, most women were of African American origin.13 Strength of evidence for nonspecific preterm labor populations from RCTs is insufficient (Table 25).

Table 25 Mean prolongation of pregnancy – Strength of evidence for nonspecific preterm labor populations

Population | N_studies_ | N_Participants_ | Strength of Evidence Domains | | | | MD (95% CI) (days) | Strength of Evidence
Population | N_studies_ | N_Participants_ | Risk of Bias | Consistency | Directness | Precision | MD (95% CI) (days) | Strength of Evidence
Singelton or Twin Gestation
RCT: SQ terbutaline pump vs. placebo10,11 | 2 | 79 | Low/High | Consistent | Indirect | Imprecise | 0.63 (-9.60,10.85) | Insufficient
RCT: SQ terbutaline pump vs. oral terbutaline11 | 1 | 30 | High | N/A | Indirect | Imprecise | 5.60 (-14.45, 25.65) | Insufficient

CI = confidence interval; MD = mean difference; RCT = randomized controlled trial; SQ = subcutaneous

##### Overall Evidence

Table 23 and Figure 10 present data for all studies that contributed to this outcome, regardless of study design and comparators. Evidence from RCTs showed indeterminate results (pooled mean difference=0.63, 95% CI: -9.6, 10.9) in contrast with evidence from observational studies of medium to high risk of bias, which showed consistent benefit. Plausible explanations include differences in study power (RCTs were underpowered compared with observational studies) and inherent risk of bias of observational study designs.

Table 23 Summary table for mean prolongation of pregnancy (overall evidence)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
RCT (2) | Women with singleton gestation from Birmingham Hospital (n=52)10 | Placebo | Low | A pooled estimate of the placebo arms of the two RCTs was nonsignificant. This result contrasts with evidence from observational studies, which showed consistent benefit in favor of SQ terbutaline pump. However, the RCT evidence is indeterminate, given the small sample sizes of both studies.
RCT (2) | Women with singleton or twin gestation from the University of Iowa Hospital (n=42)11 | Placebo and oral terbutaline | High
Prospective cohort (1) | Women with singleton gestation and RPTL (n=60)13 | No treatment | High
Retrospective cohort (4) | Women with singleton gestation and RPTL from the Matria database (n=1366)15 | Oral nifedipine | High
Retrospective cohort (4) | Women with singleton gestation and RPTL from the Matria database (n=284)17 | Oral nifedipine | Medium
Retrospective cohort (4) | Women with singleton gestation and RPTL from the Matria database (n=558)18 | Oral tocolytics (95.3% received oral terbutaline) | High
Retrospective cohort (4) | Women with twin gestation and RPTL from the Matria database (n=656)16 | Oral nifedipine | Medium

RCT = randomized controlled trial; RPTL = recurrent preterm labor; SQ = subcutaneous

#### Pregnancy Prolongation > 7 Days

Two observational studies reported pregnancy prolongation > 7 days (Table 26).15,17 Both included women with singleton gestation and RPTL from the Matria database and had oral nifedipine as a comparator. Flick et al. found that significantly more participants in the SQ terbutaline pump group had pregnancy prolonged for more than 7 days compared with the group that received oral nifedipine (OR=7.84, 95% CI: 3.59, 17.12; total number of events/sample size=1281/1366). We rated this study as high risk of bias because of group imbalances. Fleming et al., however, reported a nonsignificant difference between SQ terbutaline pump and oral nifedipine (OR=2.53, 95% CI: 0.87, 7.38; total number of events/sample size = 267/284).17 Given that the study by Flick et al. had a much larger sample size and reported a significant result, the nonsignificant difference reported by Fleming et al. may have been due to low power. We rated the study by Fleming et al. as medium risk of bias because there was insufficient information to assess several criteria, such as group comparability.

Table 26 Summary table for pregnancy prolongation > 7 days (overall evidence)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Retrospective cohort (2) | Women with singleton gestation and RPTL from the Matria database (n=1366)15 | Oral nifedipine | High | One study reported a statistically significant difference, in favor of SQ terbutaline pump15 and the other study reported a nonsignificant difference.17 The latter study may have been underpowered.
Retrospective cohort (2) | Women with singleton gestation and RPTL from the Matria database (n=284)17 | Oral nifedipine | Medium | One study reported a statistically significant difference, in favor of SQ terbutaline pump15 and the other study reported a nonsignificant difference.17 The latter study may have been underpowered.

RPTL = recurrent preterm labor; SQ = subcutaneous

#### Pregnancy Prolongation > 14 Days

Five retrospective cohorts reported pregnancy prolongation > 14 days. All of these studies used the Matria database and were exclusively in women with RPTL.

##### Subgroup: Multiple Gestation

Two studies were in women with twin gestation and both reported statistically significant differences in favor of SQ terbutaline pump, compared with oral tocolytics (OR=2.48, 95% CI: 1.65, 3.73; total number of events/sample size = 488/656 and OR=1.93, 95% CI: 1.40, 2.65; total number of events/sample size=469/706) (Table 27).16,19 We rated these studies as medium risk of bias because there was insufficient information to assess several criteria, such as group comparability.

Table 27 Summary table for pregnancy prolongation > 14 days (subgroup: multiple gestation)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Retrospective cohort (2) | Women with twin gestation and RPTL from the Matria database (n=656,)16 | Oral nifedipine | Medium | Both studies demonstrated statistically significant differences in favor of the SQ terbutaline pump.16,19 The possibility that patients on the SQ terbutaline pump overlapped between the studies cannot be ruled out.
Retrospective cohort (2) | Women with twin gestation and RPTL from the Matria database (n=706)19 | Oral tocolytics (92.3% received oral terbutaline) | Medium

RPTL = recurrent preterm labor; SQ = subcutaneous

##### Subgroup: RPTL

All studies were in women with RPTL, of either single or twin gestation (the studies in women with twin gestation have been described above) (Table 28 and Figure 11). Consistent, statistically significant differences in favor of SQ terbutaline pump compared with oral tocolytics were found across all studies (OR range=1.93-3.47, 95% CI range: 0.87-2.34, 2.65-5.15) (Figure 11).15-18 Two studies were rated as high risk of bias because of differences in baseline characteristics/prognostic factors among groups 15,18 and three were rated as medium risk of bias because there was insufficient information to assess several criteria, such as group comparability.16,17,19

Table 28 Summary table for pregnancy prolongation > 14 days (subgroup: RPTL)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Retrospective cohort (5) | Women with singleton gestation and RPTL from the Matria database (n=1366)15 | Oral nifedipine | High | All studies pertained to women with RPTL. Two of these studies were in women with twin gestation and the rest were in singletons. All studies reported statistically significant differences, in favor of the SQ terbutaline pump. Participants may have overlapped among some studies.
Retrospective cohort (5) | Women with singleton gestation and RPTL from the Matria database (n=284)17 | Oral nifedipine | Medium
Retrospective cohort (5) | Women with singleton gestation and RPTL from the Matria database (n=558)18 | Oral tocolytics (95.3% received oral terbutaline)18 | High
Retrospective cohort (5) | Women with twin gestation and RPTL from the Matria database (n=656)16 | Oral nifedipine | Medium
Retrospective cohort (5) | Women with twin gestation and RPTL from the Matria database (n=706)19 | Oral tocolytics (92.3% received oral terbutaline) | Medium

RPTL = recurrent preterm labor; SQ = subcutaneous

Figure 11 Pregnancy Prolongation > 14 Days

SQ = subcutaneous

Figure 11 displays the effect estimates for pregnancy prolongation > 14 days in a forest plot. Observational studies showed statistically significant differences, in favor of subcutaneous terbutaline pump.

#### Birth Weight

Birth weight was reported as either a continuous or dichotomous variable (i.e., incidence of low birth weight and very low birth weight) in seven observational studies, one nonrandomized trial, and two RCTs. Observational studies reported birthweight for women with twin gestation16,19 and RPTL.13,15-20 Four studies did not pertain to any specific population of interest.10-12,21 Study-level data is presented in Table F8 in Appendix F.

#### Mean Birth Weight

##### Subgroup: Multiple Gestation

As shown in Table 29, two retrospective cohort studies that compared the SQ terbutaline pump with oral tocolytics in women with twin gestation and RPTL from the Matria database reported statistically higher birth weights among infants of the SQ terbutaline pump group (mean differences in grams = 163, 95% CI: 102, 224 and 136, 95% CI 83, 189).16,19 Both studies were rated as medium risk of bias because several criteria, such as similarity in baseline characteristics and prognostic factors, could not be assessed due to incomplete reporting.

Table 29 Summary table for mean birth weight (subgroup: multiple gestation)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Retrospective cohort (2) | Women with twin gestation and RPTL from the Matria database (n=656,)16 | Oral nifedipine | Medium | Both studies reported statistically significant differences, in favor of SQ terbutaline pump. Study populations may have overlapped.
Retrospective cohort (2) | Women with twin gestation and RPTL from the Matria database (n=706)19 | Oral tocolytics (92.3% received oral terbutaline) | Medium | Both studies reported statistically significant differences, in favor of SQ terbutaline pump. Study populations may have overlapped.

RPTL = recurrent preterm labor; SQ = subcutaneous

##### Subgroup: RPTL

Table 30 presents information on studies that reported birth weight in women with RPTL. Two of these studies were in women with twin gestation, as described above.16,19 Aside from one study that reported a nonsignificant result among a study population that likely consisted of women with single and multiple gestation,20 all demonstrated statistically significant differences in favor of SQ terbutaline pump, compared with either oral tocolytics or no treatment (range of mean difference in grams was 136–721, 95% CI range: 83–355, 189–1087).13,16-19 Two studies in this body of evidence were rated as high risk of bias because of apparent differences in groups13,18 and the remaining four studies were rated as medium risk of bias because missing information prevented adequate assessment of potential limitations.16,17,19,20 The majority of this evidence came from the Matria database.16-19 The study with the no treatment comparator group included women who were mostly of African American origin13 and the study with oral terbutaline as a comparator group likely included women with single and multiple gestation, the majority of whom were classified as “nonwhite.”20

Table 30 Summary table for mean birth weight (subgroup: RPTL)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Prospective cohort (1) | Women with singleton gestation and RPTL (n=60)13 | No treatment | High | Aside from one study that included a mixture of women with single and multiple gestation,20 all reported statistically significant differences, in favor of the SQ terbutaline pump. Participants may have overlapped among some of the Matria-based studies.
Retrospective cohort (5) | Women with singleton gestation and RPTL from the Matria database (n=284) 17 | Oral nifedipine | Medium
Retrospective cohort (5) | Women with singleton gestation and RPTL from the Matria database (n=558)18 | Oral tocolytics (95.3% received oral terbutaline) | High
Retrospective cohort (5) | Women with twin gestation and RPTL from the Matria database (n=656)16 | Oral nifedipine | Medium
Retrospective cohort (5) | Women with twin gestation and RPTL from the Matria database (n=706)19 | Oral tocolytics (92.3% received oral terbutaline) | Medium
Retrospective cohort (5) | Women with RPTL and likely included a mixture of women with single and multiple gestation (n=64)20 | Oral terbutaline | Medium

RPTL = recurrent preterm labor; SQ = subcutaneous

##### Overall Evidence

Table 31 and Figure 12 present the entire body of evidence for mean difference in birthweight, regardless of subgroups. The study by Lindenbaum et al. reported discrepant results between table and text and therefore, the study estimate was deemed unreliable.12 The pooled evidence from RCTs was inconclusive (difference in means = 121.75, 95% CI: -183.55, 427.05), but type II error cannot be ruled out (Figure 12). In contrast, evidence from larger observational studies of medium to high risk of bias showed statistically higher birth weights for women receiving the SQ terbutaline pump compared with oral tocolytics.

Table 31 Summary table for mean birth weight (overall evidence)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
RCT (2) | Women with singleton gestation from Birmingham Hospital (n=52)10 | Placebo | Low | A pooled estimate of the placebo arms of the two RCTs was nonsignificant. This result is indeterminate, given the small sample sizes of both studies. Larger observational cohort studies of medium to high risk of bias showed a consistent benefit with the pump in comparison with other tocolytics.16-19 However, participants may have overlapped among some of these studies. Other observational studies demonstrated a nonsignificant difference20 or a statistically significant difference in favor of comparator.21
RCT (2) | Women with singleton or twin gestation from the University of Iowa Hospital (n=42)11 | Placebo and oral terbutaline | High
Nonrandomized trial (1) | Women with singleton gestation from the Hospital of the University of Pennsylvania (n=91)12 | Oral terbutaline | High
Prospective cohort (1) | Women with singleton gestation and RPTL (n=60)13 | No treatment | High
Retrospective cohort (6) | Women with singleton gestation and RPTL from the Matria database (n=284) 17 | Oral nifedipine | Medium
Retrospective cohort (6) | Women with singleton gestation and RPTL from the Matria database (n=558)18 | Oral tocolytics (95.3% received oral terbutaline) | High
Retrospective cohort (6) | Women with twin gestation and RPTL from the Matria database (n=656)16 | Oral nifedipine | Medium
Retrospective cohort (6) | Women with twin gestation and RPTL from the Matria database (n=706)19 | Oral tocolytics (92.3% received oral terbutaline) | Medium
Retrospective cohort (6) | Women with RPTL and likely included a mixture of women with single and multiple gestation (n=64)20 | Oral terbutaline | Medium
Retrospective cohort (6) | Women with single or multiple gestation (n=69)21 | Oral terbutaline | High

RCT = randomized controlled trial; RPTL = recurrent preterm labor

Figure 12 Mean birth weight (RCT Pooled Estimate: I^2^ = 0.0 percent, p-value > 0.05)

RCT = randomized controlled trial; SQ = subcutaneous

*Discrepancies were found in the information presented in the text and table of this paper. The numbers reported in the table were used to calculate difference in means. However, the text reported groups with the reverse numbers (i.e., SQ terbutaline pump: 3229 ± 584 and oral terbutaline: 3017 ± 303).

Figure 12 displays the effect estimates for mean birthweight in a forest plot. Larger observational studies tended to show statistically significant differences, in favor of subcutaneous terbutaline pump. Randomized controlled trials showed nonsignificant differences (pooled estimate from RCTs: I2=0.00 and p-value > 0.05).

#### Incidence of low Birth Weight

Tables 32 and 33 and Figure 13 below present studies that reported low birth weight, which was defined as < 2,500 g. All studies were observational in design.

Table 32 Summary table for incidence of low birth weight (subgroup: multiple gestation)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Retrospective cohort (2) | Women with twin gestation and RPTL from the Matria database (n=656,)16 | Oral nifedipine | Medium | Both studies reported statistically significant differences, in favor of the SQ terbutaline pump. Study populations may have overlapped.
Retrospective cohort (2) | Women with twin gestation and RPTL from the Matria database (n=706)19 | Oral tocolytics (92.3% received oral terbutaline) | Medium | Both studies reported statistically significant differences, in favor of the SQ terbutaline pump. Study populations may have overlapped.

RPTL = recurrent preterm labor; SQ = subcutaneous

Table 33 Summary table for incidence of low birth weight (subgroup: RPTL)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Prospective cohort (1) | Women with singleton gestation and RPTL (n=60)13 | No treatment | High | Statistically significant differences in favor of the pump were found in all studies. The five retrospective cohorts recruited women from the Matria database, so participants may have overlapped in some of these studies.
Retrospective cohort (5) | Women with singleton gestation and RPTL from the Matria database (n=1366)15 | Oral nifedipine | High
Retrospective cohort (5) | Women with singleton gestation and RPTL from the Matria database (n=284) 17 | Oral nifedipine | Medium
Retrospective cohort (5) | Women with singleton gestation and RPTL from the Matria database (n=558)18 | Oral tocolytics (95.3% received oral terbutaline) | High
Retrospective cohort (5) | Women with twin gestation and RPTL from the Matria database (n=656)16 | Oral nifedipine | Medium
Retrospective cohort (5) | Women with twin gestation and RPTL from the Matria database (n=706)19 | Oral tocolytics (92.3% received oral terbutaline) | Medium

RPTL = recurrent preterm labor; SQ = subcutaneous

Figure 13 Incidence of low birth weight

SQ = subcutaneous

Figure 13 displays the effect estimates for incidence of low birthweight in a forest plot. Observational studies showed statistically significant differences, in favor of subcutaneous terbutaline pump.

##### Subgroup: Multiple Gestation

Two studies were in women with twin gestation and RPTL from the Matria database (Table 32). Both reported statistically significant results in favor of SQ terbutaline pump compared with oral tocolytics (OR = 0.57, 95% CI: 0.44, 0.73; total number of events/number of infants = 975/1312 and OR = 0.64, 95% CI: 0.51, 0.80; total number of events/number of infants = 926/1393).16,19 These studies were rated as medium risk of bias because there was insufficient information to assess potential limitations.

##### Subgroup: RPTL

All studies pertained to women with RPTL (Table 33). Five of these studies were from the Matria database, so there may have been overlap in participant data.15-19 Statistically significant differences were found across all studies of medium to high risk of bias in favor of the SQ terbutaline pump, compared with oral tocolytics or no treatment (OR range = 0.24-0.64, 95% CI range: 0.06-0.51, 0.62-0.96). The majority of women in the prospective cohort with the no treatment comparator group were of African American origin.13

#### Incidence of Very low Birth Weight

Tables 34 and 35 and Figure 14 below present studies that reported incidence of very low birthweight, which was defined as < 1,500 g.

Table 34 Summary table for incidence of very low birth weight (subgroup: multiple gestation)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Retrospective cohort (2) | Women with twin gestation and RPTL from the Matria database (n=656,)16 | Oral nifedipine | Medium | Both studies reported statistically significant differences, in favor of SQ terbutaline pump. Study populations may have overlapped.
Retrospective cohort (2) | Women with twin gestation and RPTL from the Matria database (n=706)19 | Oral tocolytics (92.3% received oral terbutaline) | Medium | Both studies reported statistically significant differences, in favor of SQ terbutaline pump. Study populations may have overlapped.

RPTL = recurrent preterm labor; SQ = subcutaneous

Table 35 Summary table for incidence of very low birth weight (subgroup: RPTL)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Retrospective cohort (4) | Women with singleton gestation and RPTL from the Matria database (n=284) 17 | Oral nifedipine | Medium | All studies pertained to women with RPTL and most demonstrated statistically significant differences in favor of SQ terbutaline pump. One study, which showed a nonsignificant difference may have been underpowered.17 Study populations may have overlapped.
Retrospective cohort (4) | Women with singleton gestation and RPTL from the Matria database (n=558)18 | Oral tocolytics (95.3% received oral terbutaline) | High
Retrospective cohort (4) | Women with twin gestation and RPTL from the Matria database (n=656)16 | Oral nifedipine | Medium
Retrospective cohort (4) | Women with twin gestation and RPTL from the Matria database (n=706)19 | Oral tocolytics (92.3% received oral terbutaline) | Medium

RPTL = recurrent preterm labor; SQ = subcutaneous

Figure 14 Incidence of very low birth weight

SQ = subcutaneous

Figure 14 displays the effect estimates for incidence of very low birthweight in a forest plot. Observational studies showed statistically significant differences, in favor of subcutaneous terbutaline pump.

##### Subgroup: Multiple Gestation

Two of these studies were in women with twin gestation and RPTL from the Matria database (Table 34). Both reported statistically significant results in favor of SQ terbutaline pump compared with oral tocolytics (OR = 0.40, 95% CI: 0.26, 0.60; total number of events/number of infants = 156/1312 and OR=0.46, 95% CI: 0.29, 0.73; total number of events/sample size = 88/1393) (Table 32).16,19 These studies were rated as medium risk of bias because there was insufficient information to assess potential limitations.

##### Subgroup: RPTL

All studies pertained to women with RPTL (Table 35).16-19 Aside from the study by Fleming et al, which showed a nonsignificant result,17 statistically significant differences were found across all studies of medium to high risk of bias in favor of SQ terbutaline pump, compared with oral tocolytics (OR range = 0.22–0.46, 95% CI range: 0.07–0.29, 0.60–0.73).16,18,19 No apparent explanations for this inconsistency in effect estimates could be found. However, the Fleming et al. study had the smallest sample size and, therefore, it may have been underpowered to detect a difference in this outcome.

All subsequent outcomes are presented at the study-level in Table F9 in Appendix F.

#### Mean Pregnancy Prolongation Index

Two observational studies defined pregnancy prolongation index as the ratio of the number of days from RPTL to delivery divided by the number of days to 37 weeks' gestation (i.e., the desired prolongation) (Table 36).13,20 Both studies were in women with RPTL and showed statistically significant differences in favor of the SQ terbutaline pump, compared with oral terbutaline or no treatment (mean difference = 0.41, 95% CI: 0.26, 0.56; and 0.14, 95% CI: 0.02-0.26).13,20 One study was rated as high risk of bias because groups were clearly imbalanced in risk factors for preterm birth, primary tocolytic therapy, and level of care.13 The other study was rated as medium risk of bias because several criteria were rated as unclear due to incomplete reporting.20 One study pertained to women with singleton gestation, the majority of whom were of African American origin13 and the other study likely included women with single and multiple gestation, the majority of whom were classified as “nonwhite.”20

Table 36 Summary table for mean pregnancy prolongation index (subgroup: RPTL)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Prospective cohort (1) | Women with singleton gestation and RPTL (n=60)13 | No treatment | High | Both studies reported statistically significant differences, in favor of SQ terbutaline pump.
Retrospective cohort (1) | Women with RPTL and likely included a mixture of women with single and multiple gestation (n=64)20 | Oral terbutaline | Medium | Both studies reported statistically significant differences, in favor of SQ terbutaline pump.

RPTL = recurrent preterm labor; SQ = subcutaneous

#### Need for Assisted Ventilation

One retrospective cohort that compared the SQ terbutaline pump with oral tocolytics in women with singleton gestation and RPTL from the Matria database reported requirement for ventilator among infants with NICU admission.18 This study reported a nonsignificant difference (OR = 0.91, 95% CI: 0.62, 1.33; total number of events/sample size = 141/558). We rated this study as high risk of bias because there were apparent differences among groups in baseline characteristics and prognostic factors.

#### Incidence of NICU Admission

Seven studies reported incidence of NICU admission. Six observational studies, mostly from the Matria database, reported data for women with twin gestation and RPTL (Tables 37 and 38).13,15-19 In addition, one underpowered RCT of low risk of bias showed no difference between SQ terbutaline pump and placebo in women with singletons (Figure 15) (total number of events/sample size = 23/51).10

Table 37 Summary table for incidence of NICU admission (subgroup: multiple gestation)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Retrospective cohort (2) | Women with twin gestation and RPTL from the Matria database (n=656,)16 | Oral nifedipine | Medium | Both studies reported statistically significant differences, in favor of SQ terbutaline pump. Study populations may have overlapped.
Retrospective cohort (2) | Women with twin gestation and RPTL from the Matria database (n=706)19 | Oral tocolytics (92.3% received oral terbutaline) | Medium | Both studies reported statistically significant differences, in favor of SQ terbutaline pump. Study populations may have overlapped.

RPTL = recurrent preterm labor; SQ = subcutaneous

Table 38 Summary table for incidence of NICU admission (subgroup: RPTL)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Prospective cohort (1) | Women with singleton gestation and RPTL (n=60)13 | No treatment | High | All observational studies pertained to women with RPTL and reported statistically significant differences in favor of the SQ terbutaline pump. Participant data may have overlapped in the Matria-based studies.
Retrospective cohort (5) | Women with singleton gestation and RPTL from the Matria database (n=1366)15 | Oral nifedipine | High
Retrospective cohort (5) | Women with singleton gestation and RPTL from the Matria database (n=284) 17 | Oral nifedipine | Medium
Retrospective cohort (5) | Women with singleton gestation and RPTL from the Matria database (n=558)18 | Oral tocolytics (95.3% received oral terbutaline) | High
Retrospective cohort (5) | Women with twin gestation and RPTL from the Matria database (n=656)16 | Oral nifedipine | Medium
Retrospective cohort (5) | Women with twin gestation and RPTL from the Matria database (n=706)19 | Oral tocolytics (92.3% received oral terbutaline) | Medium

RCT = randomized controlled trial; RPTL = recurrent preterm labor; SQ = subcutaneous

Figure 15 NICU admission incidence

RCT = randomized controlled trial; SQ = subcutaneous

Figure 15 displays the effect estimates for incidence of NICU admission in a forest plot. Observational studies showed statistically significant differences, in favor of subcutaneous terbutaline pump. One randomized controlled trial showed a nonsignificant difference.

##### Subgroup: Multiple Gestation

Two studies were in women with twin gestation and RPTL from the Matria database (Table 37). Both reported statistically significant results in favor of SQ terbutaline pump compared with oral tocolytics (OR = 0.72, 95% CI: 0.58, 0.91; total number of events/number of infants = 655/1312) and OR = 0.51, 95% CI: 0.41, 0.63; total number of events/sample size = 650/1393) (Table 38).16,19 These studies were rated as medium risk of bias because there was insufficient information to assess potential limitations.

##### Subgroup: RPTL

All observational studies, including the two studies in women with twin gestation described above, pertained to women with RPTL (Table 38).13,15-19 These studies were of medium to high risk of bias and five studies used the Matria database.15-19 Overall, a consistent and significant benefit associated with pump was noted across the observational studies (OR range 0.28–0.72, 95% CI range: 0.08–0.58, 0.63–0.97).

#### NICU Mean Length of Stay

Five studies reported data on NICU mean length of stay. Four observational studies, primarily from the Matria database, were available in women with RPTL13,15,18,19; one of these studies was additionally in women with twin gestation (Table 39 and Figure 16). These studies were mostly of high risk of bias. All reported statistically significant differences in favor of SQ terbutaline pump, compared with oral tocolytics or no treatment (range of mean difference in days: -3.50 to -17.90, 95% CI range: -5.26 to -32.88, -1.74 to -3.54). One RCT, which did not specifically pertain to any of the populations of interest, was conducted in women with single and twin gestation.11 This study reported a statistically nonsignificant differences for the SQ terbutaline pump compared with placebo or oral terbutaline.11 The plausible explanation for discrepant results between the RCT and observational evidence is inadequacy of study power.

Table 39 Summary table for NICU length of stay (subgroup: RPTL)

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Prospective cohort (1) | Women with singleton gestation and RPTL (n=60)13 | No treatment | High | All studies reported statistically significant differences, in favor of the SQ terbutaline pump. Participant data in the SQ terbutaline pump groups of the Matria studies in singleton gestation may have overlapped.
Retrospective cohort (3) | Women with singleton gestation and RPTL from the Matria database (n=1366)15 | Oral nifedipine | High
Retrospective cohort (3) | Women with singleton gestation and RPTL from the Matria database (n=558)18 | Oral tocolytics (95.3% received oral terbutaline) | High
Retrospective cohort (3) | Women with twin gestation and RPTL from the Matria database (n=706)19 | Oral tocolytics (92.3% received oral terbutaline) | Medium

NICU = neonatal intensive care unit; RPTL = recurrent preterm labor; SQ = subcutaneous

Figure 16 NICU length of stay

NICU = neonatal intensive care unit; RCT = randomized controlled trial; SQ = subcutaneous

Figure 16 displays the effect estimates for NICU length of stay in a forest plot. Observational studies showed statistically significant differences, in favor of subcutaneous terbutaline pump. One randomized controlled trial showed nonsignificant differences.

## Key Question 3 Maternal Harms

In women with arrested preterm labor, does treatment with a SQ infusion of terbutaline delivered by a pump, in comparison with placebo, conservative treatment, or other interventions increase the maternal harms of arrhythmia, heart failure, hyperglycemia, hypokalemia, maternal mortality, myocardial infarction, pulmonary edema, refractory hypotension, or result in an increased rate of maternal discontinuation of therapy or maternal withdrawal due to adverse effects (Withdrawal-AE)?

### Key Points

- Strength of evidence is insufficient for Withdrawal-AE.
- Tachycardia/nervousness was significantly higher among women who received the SQ terbutaline pump in comparison with no treatment in a prospective cohort of women with singleton gestation and RPTL, although the point estimate was unreliable.
- Underpowered studies demonstrated indeterminate results for the outcomes of mortality, pulmonary edema, and therapy discontinuation (i.e., type II error cannot be excluded).
- Two studies demonstrated nonsignificant differences between the SQ terbutaline pump and oral terbutaline in the incidence of gestational diabetes, though type II error cannot be excluded.
- No data were available for the following outcomes: heart failure, hypokalemia, myocardial infarction, or refractory hypotension.
- FDA postmarketing surveillance has identified at least three maternal deaths and three cases of cardiovascular adverse events associated with the use of SQ terbutaline delivered by pump.

### Detailed Analysis

Table F10 in Appendix F presents data for Key Question 3. None of the included studies reported data on heart failure, hypokalemia, myocardial infarction, refractory hypotension, or Withdrawal-AE (strength of evidence is insufficient). The evidence and determinants of applicability are presented below by outcome. Summary tables are presented if more than one study was available for an outcome; otherwise, all information has been summarized in the text.

#### Arrhythmia

In a prospective cohort study of women with singleton gestation and RPTL, Morrison et al. reported three cases of tachycardia/nervousness in women receiving the SQ terbutaline pump compared with no cases in the control group (OR=25.48, 95% CI: 1.23, 526.64).13 We rated this study as high risk of bias because groups were imbalanced in risk factors for preterm birth, primary tocolytic therapy, and level of care. This evidence pertained to women with singleton gestation and RPTL, the majority of whom were of African American origin. However, given that the outcome was not restricted to arrhythmia specifically (i.e., nervousness was included), applicability is limited.

#### Hyperglycemia

Two studies reported data on gestational diabetes, diagnosed by 3-hour glucose tolerance test (GTT) (Table 40). Studies were not pooled because of heterogeneity in study designs and patient populations. Type II error cannot be excluded for the available evidence because these studies may be underpowered.

Table 40 Summary table for maternal hyperglycemia

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Retrospective cohort (1) | Women with single or multiple gestation (n=69)21 | Oral terbutaline | High | Both studies reported nonsignificant differences in the incidence of gestational diabetes. Possibility of type II error cannot be excluded.
Nonrandomized trial (1) | Women with singleton gestation from the Hospital of the University of Pennsylvania (n=91)12 | Oral terbutaline | Medium | Both studies reported nonsignificant differences in the incidence of gestational diabetes. Possibility of type II error cannot be excluded.

In a retrospective cohort, Regenstein et al. found a higher percentage of gestational diabetes among women in the SQ terbutaline pump group compared with the oral terbutaline group, but the difference was statistically nonsignificant (OR=1.94, 95% CI: 0.49, 7.65; total number of events/sample size=10/65).21 This study included women with single or multiple gestations, the majority of whom were Caucasian.

Lindenbaum et al. conducted a nonrandomized trial in women with singleton gestation from a university hospital and found a lower percentage of gestational diabetes among women in the SQ terbutaline pump group compared with the oral terbutaline group. This result was also statistically nonsignificant (OR=0.46, 95% CI: 0.09, 2.40; total number of events/sample size=8/91).12 The study by Lindenbaum et al. only included women who demonstrated normal 1-hour oral GTT between 24 to 28 weeks' gestation, so this study population may have been at lower risk for gestational diabetes than the population recruited by Regenstein et al.

#### Mortality

Two retrospective cohort studies investigated maternal mortality (Table 41). Lam et al. (2003) studied women with singleton gestation and RPTL18 and Lam et al. (2001) studied women with twin gestation and RPTL.19 Both studies used oral tocolytics as comparators. No maternal deaths were reported in either study.18,19

Table 41 Summary table for mortality

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Retrospective cohort (2) | Women with singleton gestation and RPTL from the Matria database (n=558)18 | Oral tocolytics (95.3% received oral terbutaline) | High | No events reported.
Retrospective cohort (2) | Women with twin gestation and RPTL from the Matria database (n=706)19 | Oral tocolytics (92.3% received oral terbutaline) | Medium | No events reported.

RPTL = recurrent preterm labor

#### Pulmonary Edema

Lam et al. (2003) and Lam et al. (2001) also reported data on pulmonary edema (Table 42).18,19 Lam et al. (2003) observed one case of pulmonary edema in the oral tocolytic group (OR=0.33, 95% CI: 0.01, 8.19) and Lam et al. (2001) observed one case in the SQ terbutaline pump group (OR=3.01, 95% CI: 0.12, 74.11).18,19 Both studies were likely underpowered to detect a difference due to low event rates.

Table 42 Summary table for pulmonary edema

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Retrospective cohort (2) | Women with singleton gestation and RPTL from the Matria database (n=558)18 | Oral tocolytics (95.3% received oral terbutaline) | High | Both studies found statistically nonsignificant differences between SQ terbutaline pump and oral tocolytics. However, they were likely underpowered.
Retrospective cohort (2) | Women with twin gestation and RPTL from the Matria database (n=706)19 | Oral tocolytics (92.3% received oral terbutaline) | Medium | Both studies found statistically nonsignificant differences between SQ terbutaline pump and oral tocolytics. However, they were likely underpowered.

RPTL = recurrent preterm labor; SQ = subcutaneous

#### Therapy Discontinuation

One prospective cohort and one RCT investigated maternal discontinuation of therapy (Table 43).10,13 Morrison et al. reported no discontinuation of therapy in a prospective cohort of women with singleton gestation and RPTL.13 Guinn et al. reported a higher percentage of treatment discontinuation among women with singleton gestation randomized to the SQ terbutaline pump group compared with placebo, but this difference was statistically nonsignificant (OR=1.79, 95% CI: 0.58, 5.52; total number of events/sample size=20/52).10 The RCT was likely underpowered to detect a difference for this outcome.

Table 43 Summary table for maternal discontinuation of therapy

Study Design (Number of Studies) | Population | Comparator(s) | Risk of Bias | Overall Findings
Prospective cohort (1) | Women with singleton gestation and RPTL (n=60)13 | No treatment | High | No women discontinued treatment in the prospective cohort. In the RCT, discontinuation was higher in the SQ terbutaline pump group compared with placebo, but the difference was statistically nonsignificant (OR=1.79, 95% CI: 0.58, 5.52). Type II error cannot be excluded.
RCT (1) | Women with singleton gestation from Birmingham Hospital (n=52)10 | Placebo | Low

CI = confidence interval; OR = odds ratio; RCT = randomized controlled trial; RPTL = recurrent preterm labor; SQ = subcutaneous

Until 2009, 16 maternal deaths and 12 cases of maternal cardiovascular events (hypertension, myocardial infarction tachycardia, arrhythmias, and pulmonary edema) in association with terbutaline tocolysis were reported to the FDA. Of these, at least three maternal deaths and three cardiovascular adverse events were clearly reported to be in association with the use of the SQ terbutaline pump.24

## Key Question 4 Neonatal Harms

In women with arrested preterm labor, does treatment with an SQ infusion of terbutaline delivered by a pump, in comparison with placebo, conservative treatment, or other interventions increase the neonatal harms of hypoglycemia, hypocalcemia, and ileus?

### Key Points

- One case of hypoglycemia was reported in the placebo group of an underpowered RCT.11
- No data were available for the outcomes of hypocalcemia and ileus.

### Detailed Analysis

Table F11 in Appendix F presents data for Key Question 4. No information was available for hypocalcemia or ileus. Hypoglycemia was reported by Wenstrom et al. in an RCT of women with single or twin gestation recruited from a university hospital in the United States.11 This study compared the SQ terbutaline pump with placebo and oral terbutaline. One case of hypoglycemia was observed in the placebo group. No cases were reported among women who received the SQ terbutaline pump or oral terbutaline (OR=0.25, 95% CI: 0.01, 6.53 for SQ terbutaline pump versus placebo). The occurrence of a single hypoglycemic event among a sample size of 42 participants indicates that this study was underpowered to detect a difference in this outcome. Furthermore, we rated this study as high risk of bias because of selection bias, limitations in study power, and absence of blinding.

## Key Question 5 Level of Activity and Level of Care

Can the differences in the outcomes above be partially explained by differences in level of care (e.g., frequency of followup, nurse visits, concomitant treatment, etc.) and level of activity (e.g., other children in the home, marital/support status, working status, bed rest, etc.) between the terbutaline pump group and the comparator group?

### Key Points

- Few studies reported the level of maternal activity and the level of maternal care as study-level covariates, precluding meta-regression on outcomes.
- Qualitative analysis revealed no apparent trends between level of activity or level of care and the outcomes specified in Key Questions 1–4.

### Detailed Analysis

Ratings for level of maternal activity and level of maternal care are provided in Appendix F, Tables F13 and F15. These tables provide overall ratings for each study, as well as ratings for the individual variables that comprise the level of activity and level of care variables.

#### Level of Maternal Activity

Level of maternal activity could not be rated for most studies due to insufficient information (i.e., incomplete reporting of marital status, working status, caring for other children, social support, bed rest, and restriction of maternal activities).10,12,14-19,21 The participants in other studies were rated as having a low level of maternal activity, primarily because they were advised to remain at bed rest.11,13,20,22,23 Level of activity in these studies did not vary by treatment groups, so these ratings represented study-level covariates.

#### Level of Maternal Care

Level of maternal care could not be rated for three studies due to insufficient information (i.e., incomplete reporting of nursing assessments, home uterine activity monitoring, home visits, education about preterm labor, telephone support, restriction of maternal activities, and other cointerventions).11,12,21 Table 44 below summarizes ratings for all other studies. In two studies, level of care was found to vary among the SQ terbutaline pump and comparator groups and, therefore, in these cases it was not a study-level covariate.13,20

Table 44 Studies that could be rated for level of maternal care

First Author (Year) | Rating (Low, Moderate, High)
Flick (2010)15 | High
de la Torre (2008)16 | High
Fleming (2004)17 | High
Lam (2003)18 | High
Morrison (2003)13 | SQ terbutaline pump group: High Control group: Moderate
Lam (2001)19 | High
Allbert (1994)20 | SQ terbutaline pump group: High Control group: Moderate
Guinn (1998)10 | Moderate
Adkins (1993)22 | Moderate
Morrison (1992)14 | Moderate
Lam (1988)23 | High

SQ = subcutaneous

### Evidence Synthesis

A minimum of 12 studies were needed to explore the effect of level of activity or level of care on the outcomes specified in Key Questions 1–4 through meta-regression (number of studies needed is equal to 6×(n-1) for n levels for a categorical covariate). Studies were to be considered for meta-regression only if all of the following criteria were satisfied: there was no within-study confounding by level of activity or level of care, studies were not rated as unclear, and studies were similar enough with respect to patient population, intervention, and comparator.

A meta-regression could not be conducted for level of activity because sufficient information was available to rate only five studies. Furthermore, it was impossible to assess the impact of level of activity on effect estimates even in a qualitative manner because all five studies were rated as “low.”

Similarly, a meta-regression could not be conducted for level of care because only 11 studies were ratable and, of these, 2 were confounded by level of care. Of the remaining nine studies, three were rated as moderate 10,14,19,22 and six were rated as high.15-18,23 These studies were qualitatively examined to explore trends in effect estimates by level of care. No trends were apparent between level of care and any of the outcomes in Key Questions 1–4.

## Key Question 6 Incidence of Pump Failure

What is the incidence of failure of the pump device used for terbutaline infusion, including missed doses, dislodgment, and overdose?

### Key Points

- Based on evidence from a case series, the incidence of dislodgement and pump malfunction were 2 percent (exact central CI, 0.5%, 10%).
- An underpowered RCT demonstrated indeterminate results for the outcomes of local pain and local skin irritation.
- No data were available for the outcomes of missed doses or overdose.

### Detailed Analysis

Table F16 in Appendix F presents data for Key Question 6. None of the studies reported data on the incidence of missed doses or overdose. At least one study reported data on dislodgment and other pump-related outcomes, including infusion site infection, local pain, local skin irritation, and pump malfunction/mechanical failures and complications. The following pump manufacturers and models were reported in the studies: Adkins et al. used pump model 404-SP from MiniMed Technologies22; Lam et al. used pump model Autosyringe AS6-C U300 from Travenol, Deerfield, IL23; and Wenstrom et al. used pumps from Minimed Technologies (model not specified).11 The sites of implantation were not reported in any study.

#### Dislodgment

Adkins et al. conducted a case series analysis of 51 women prescribed the SQ terbutaline pump and found one participant with catheter dislodgment (2 percent, exact central CI: 0.5%, 10%).22

#### Other Pump-Related Outcomes

Lam et al. found no infusion site infections in a case series analysis of nine women on the SQ terbutaline pump.23

Wenstrom et al. reported two cases of local pain among women randomized to the SQ terbutaline pump group and two cases in the placebo group.11 This study also reported one case of local skin irritation in the SQ terbutaline pump group. Results for both local pain and local skin irritation were statistically nonsignificant when compared with either placebo or oral terbutaline (local pain: OR=0.77, 95% CI: 0.09, 6.45 for placebo and OR=5.74, 95% CI: 0.25, 130.38 for oral terbutaline; local skin irritation: OR=2.59, 95% CI: 0.10, 69.34 for placebo and OR=3.21, 95% CI: 0.12, 85.21 for oral terbutaline). However, given the sparse event rates, this RCT was likely underpowered to detect differences in either outcome.

The outcomes of pump malfunction/mechanical failures and complications were reported by two case series.22,23 Lam et al. observed no events in a case series of nine women.23 Adkins et al. reported an incidence of 2 percent (exact central CI, 0.5%, 10%) in a case series of 51 women.22

### Overall Applicability for Body of Evidence

Table 45 Applicability assessment by the PICOTS domains

Population | | Overall Conclusions
Inclusion/exclusion criteria | Most studies included women exclusively with RPTL.13-20,23 In other studies, RPTL was not mentioned as an inclusion criterion, so it is unclear whether these populations consisted of women with single or multiple preterm labor episodes.10-12,21,22 | The majority of evidence pertained to women with RPTL and singleton gestation. A couple of studies included women exclusively with RPTL and twin gestations; these participants represent a particularly high-risk, specialized group of patients.16,19 Very little is known about the study populations' demographic and clinical characteristics. Furthermore, the possibility that participants represent a select group of individuals cannot be entirely ruled out for a large proportion of the evidence base due to poor reporting of exclusion rates and sampling methodology. Nine of 14 studies (64 percent) included women judged to be in labor on account of persistent contractions and cervical change. The definition of labor was unclear in other studies. Among the evidence that suggested that the pump was efficacious, 50 percent reported cervical change and contractions as part of the definition of labor while 50 percent did not report how labor was defined.
Demographic characteristics | Several studies (n=9) took place at single centers in the United States with limited demographic information.10-14,20-23 Although age was reported in most of the single-center studies and race in some, there was little information on measures of socioeconomic status. Other studies included patients from a U.S.-based national database run by Matria Healthcare (now called Alere). These studies reported information on age and marital status but, as with the single-center studies, complete demographic information was lacking.
Exclusion rate | The overall impact on applicability due to participant exclusion is unknown for much of the evidence because many studies did not report an exclusion rate. In one RCT, more than 90 percent of the eligible population declined to participate.11
Run-in period (attrition before randomization) | In the two RCTs included in the review, no issues pertaining to run-in period were identified.
Intervention | | Overall Conclusions
Dose and duration | The dose and duration of the SQ terbutaline pump were generally typical of those used in clinical practice. However, some studies failed to provide adequate information regarding bolus and basal doses to allow assessment. | No major issues were identified with respect to the intervention, although there were gaps in reporting. Very few details were reported on cointerventions that could modify the effectiveness of therapy.
Level of care and training on pump administration | The level of care and training provided on pump administration were also deemed to be typical in most studies but, again, this information was not reported in some instances. In several studies, patients received specialized outpatient support, which may not be typical of practice.
Cointerventions | Cointerventions with the potential to affect outcomes were considered to be bed rest, restriction of maternal activities, and administration of betamethasone. Corticosteroid use was reported in only one study, and details about bed rest and restriction of maternal activities were rarely reported.
Comparison | | Overall Conclusions
Dose/schedule and whether comparator is best available alternative | Several types of comparison groups were used in the studies. No issues were identified in the studies with an active treatment comparison group that would limit applicability. | No serious limitations to applicability due to comparators were identified.
Outcomes | | Overall Conclusions
Clinical benefits (versus surrogate) | At least one clinical outcome was reported in most studies (i.e., neonatal outcomes of NEC, IVH, retinopathy of prematurity, sepsis, stillbirth, death; neonatal harm of hypoglycemia; and maternal harms of pulmonary edema, arrhythmia, hyperglycemia, death, and discontinuation of therapy). A few studies only reported surrogate outcomes (i.e., gestational age at delivery, birth weight, prolongation of pregnancy, or NICU admission). None of the studies reported any long-term outcomes such as childhood development, neurobehavioral testing, lung function, or vision. | Surrogate outcomes are the most commonly reported in this literature. Data on clinical outcomes and neonatal/maternal harms, including pump-related outcomes, is sparse. Several important clinical outcomes have not been reported. Assessment of long-term outcomes are also absent.
Individual harms and how defined | At least one neonatal or maternal harm outcome was reported in several studies. Very few studies reported outcomes related to the pump.
Timing of Followup | | Overall Conclusions
Timing of followup | In all studies, outcomes were assessed up to the point of delivery. | The absence of followup beyond delivery is a major limitation because important long-term outcomes were not evaluated.
Setting | | Overall Conclusions
Geographic setting (standards of care) | All studies took place in the United States. Most studies were conducted at single study centers, and the remaining used a national database of women who were referred to an outpatient perinatal program. Most studies that took place at single study centers were at teaching hospitals, although one study took place at a private urban obstetrics and gynecology group practice. | All studies were from the United States, and participants were recruited either from a national database (Matria) or from single center sites. Women from the Matria database generally received a high level of care from an outpatient perinatal program. However, the distribution of regions from which patients were recruited into the national database is unknown and information about the standards followed by the individual practice sites that provided obstetrical care was not reported. Similarly, for those studies that took place at single center sites, the standards of care followed at these sites are unclear.
Clinical setting (level of care and population) | Women recruited into the national database received services from a specialized perinatal program that consisted of 24-hour nursing and pharmacy support, home uterine activity monitoring, individualized education, and provision of tocolytic therapy, including the SQ terbutaline pump. All women in these studies had RPTL and were either exclusively of singleton or twin gestation. Details of the clinical setting in the single-center studies were reported inconsistently. Some studies reported the provision of patient education, telephone support, home visits, and/or home uterine activity monitoring.

IVH = intraventricular hemorrhage; NEC = necrotizing enterocolitis; NICU = neonatal intensive care unit; PICOTS = population, intervention, comparison, outcome, timing, setting; RCT = randomized controlled trial; RPTL = recurrent preterm labor; SQ = subcutaneous