# References

1 Behrman R, Butler A. Preterm Birth: Causes, Consequences, and Prevention. Washington, DC. National Academies Press. 2007.
2 Centers for Disease Control and Prevention. Birthweight and Gestation. Available at: www.cdc.gov/nchs/fastats/birthwt.htm. May 12, 2010.
3 Mathews TJ, MacDorman MF. Infant mortality statistics from the 2006 period linked birth/infant death data set. Natl Vital Stat Rep. Apr. 30. 2010;58(17):1-31. [pmid: 20815136].
4 Nanda K, Cook LA, Gallo MF, et al. Terbutaline pump maintenance therapy after threatened preterm labor for preventing preterm birth. Cochrane Database Syst Rev. Dec. 2002;(4).
5 HAYES, Inc. Continuous subcutaneous terbutaline infusion for treatment of preterm labor (Structured abstract). Lansdale, Pa. Hayes, Inc. 2006.
6 Hayes E, Moroz L, Pizzi L, et al. A cost decision analysis of 4 tocolytic drugs. Am J Obstet Gynecol. Oct. 2007;197(4):383-6. [pmid: 17904969].
7 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews[Draft]. AHRQ Publication No. 10(11)-EHC063-EF. Available at: www.effectivehealthcare.ahrq.gov/ehc/products/60/318/Methods-Guide_Prepublication-Draft_03-2011.pdf. Rockville, MD. 2011.
8 Santaguida P, Raina P. McMaster Quality Assessment Scale of Harms (McHarm) for primary studies: Manual for use of the McHarm. Available at: http://hiru.mcmaster.ca/epc/mcharm.pdf. December 22, 2010.
9 Owens DK, Lohr KN, Atkins D, et al. AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions--agency for healthcare research and quality and the effective healthcare program, J Clin Epidemiol. May. 2010;63(5):513-23. [pmid: 19595577].
10 Guinn DA, Goepfert AR, Owen J, et al. Terbutaline pump maintenance therapy for prevention of preterm delivery: a double-blind trial. [see comment]. Am J Obstet Gynecol. Oct. 1998;179(4):874-8. [pmid: 9790362].
11 Wenstrom KD, Weiner CP, Merrill D, et al. A placebo-controlled randomized trial of the terbutaline pump for prevention of preterm delivery. Am J Perinatol. Feb. 1997;14(2):87-91. [pmid: 9259905].
12 Lindenbaum C, Ludmir J, Teplick FB, et al. Maternal glucose intolerance and the subcutaneous terbutaline pump. Am J Obstet Gynecol. Mar. 1992;166(3):925-8. [pmid: 1550166].
13 Morrison JC, Chauhan SP, Carroll CS Sr, et al. Continuous subcutaneous terbutaline administration prolongs pregnancy after recurrent preterm labor. Am J Obstet Gynecol. Jun. 2003;188(6):1460-5. [pmid: 12824979].
14 Morrison JC, Allbert JR, Floyd RC, et al. Interval to delivery in high-risk patients: Do tocolytic agents really work?. Int J Gynaecol Obstet. 1992;38(3):189-93. [pmid: 1360420].
15 Flick AA, de la Torre L, Roca LE, et al. An examination of the clinical benefits and cost-effectiveness of tocolytic replacement following recurrent preterm labor. Am J Perinatol. Jan. 2010;27(1):53-9. [pmid: 19823965].
16 de la Torre L, Istwan NB, Desch C, et al. Management of recurrent preterm labor in twin gestations with nifedipine tocolysis. Am J Perinatol. Oct. 2008;25(9):555-60. [pmid: 18773381].
17 Fleming A, Bonebrake R, Istwan N, et al. Pregnancy and economic outcomes in patients treated for recurrent preterm labor. J Perinatol. Apr. 2004;24(4):223-7. [pmid: 14999214].
18 Lam F, Istwan NB, Jacques D, et al. Managing perinatal outcomes: the clinical benefit and cost-effectiveness of pharmacologic treatment of recurrent preterm labor. Managed Care. Jul. 2003;12(7):39-46. [pmid: 12891954].
19 Lam F, Bergauer NK, Jacques D, et al. Clinical and cost-effectiveness of continuous subcutaneous terbutaline versus oral tocolytics for treatment of recurrent preterm labor in twin gestations. J Perinatol. Oct. 2001;21(7):444-50. [pmid: 11894512].
20 Allbert JR, Johnson C, Roberts WE, et al. Tocolysis for recurrent preterm labor using a continuous subcutaneous infusion pump. J Reprod Med. Aug. 1994;39(8):614-8. [pmid: 7996525].
21 Regenstein AC, Belluomini J, Katz M. Terbutaline tocolysis and glucose intolerance. Obstet Gynecol. May. 1993;81(5 ( Pt 1)):739-41. [pmid: 8469464].
22 Adkins RT, Van Hooydonk JE, Bressman PL, et al. Prevention of preterm birth: early detection and aggressive treatment with terbutaline. [see comment]. South Med J. Feb. 1993;86(2):157-64. [pmid: 8240475].
23 Lam F, Gill P, Smith M, et al. Use of the subcutaneous terbutaline pump for long-term tocolysis. Obstet Gynecol. Nov. 1988;72(5):810-3. [pmid: 3173932].
24 U.S. Food and Drug Administration. FDA Drug Safety Communication: New warnings against use of terbutaline to treat preterm labor. Available at: www.fda.gov/Drugs/DrugSafety/ucm243539.htm. April 7, 2011.
25 Chou R, Aronson N, Atkins D, et al. AHRQ series paper 4: assessing harms when comparing medical interventions: AHRQ and the effective health-care program. J Clin Epidemiol. May. 2010;63(5):502-12. [pmid: 18823754].
26 Zwarenstein M, Treweek S, Gagnier JJ, et al. Improving the reporting of pragmatic trials: an extension of the CONSORT statement. BMJ. 2008;337:a2390. [pmid: 19001484].
27 Iams J, Romero R, Creasy R. Preterm labor and birth. Creasy R, Resnik R, Iams J, editors. Creasy and Resnik's Maternal-fetal medicine: principles and practice. 6th ed. Philadelphia PA. Saunders Elsevier. 2010:545-82.
28 Martin JA, Osterman MJ, Sutton PD. Are preterm births on the decline in the United States? Recent data from the National Vital Statistics System. NCHS Data Brief. May. 2010;(39):1-8. [pmid: 20604990].
29 Ananth CV, Vintzileos AM. Epidemiology of preterm birth and its clinical subtypes. J Matern Fetal Neonatal Med. Dec. 2006;19(12):773-82. [pmid: 17190687].
30 King JF, Grant A, Keirse MJ, et al. Beta-mimetics in preterm labour: an overview of the randomized controlled trials. Br J Obstet Gynaecol. Mar. 1988;95(3):211-22. [pmid: 2897207].
31 Hueston WJ. Preterm contractions in community settings: II. Predicting preterm birth in women with preterm contractions. Obstet Gynecol. Jul. 1998;92(1):43-6. [pmid: 9649090].
32 Macones GA, Segel SY, Stamilio DM, et al. Prediction of delivery among women with early preterm labor by means of clinical characteristics alone. Am J Obstet Gynecol. Dec. 1999;181(6):1414-8. [pmid: 10601922].
33 Bastek JA, Sammel MD, Pare E, et al. Adverse neonatal outcomes: examining the risks between preterm, late preterm, and term infants. Am J Obstet Gynecol. Oct. 2008;199(4):367-8. [pmid: 18928976].
34 Weismiller DG. Preterm labor. Am Fam Physician. Feb. 1. 1999;59(3):593-602. [pmid: 10029786].
35 Sebire NJ, Jolly M, Harris J, et al. Is maternal underweight really a risk factor for adverse pregnancy outcome? A population-based study in London. BJOG. Jan. 2001;108(1):61-6. [pmid: 11213006].
36 Dole N, Savitz DA, Hertz-Picciotto I, et al. Maternal stress and preterm birth. Am J Epidemiol. Jan. 1. 2003;157(1):14-24. [pmid: 12505886].
37 Rust OA, Bofill JA, Arriola RM, et al. The clinical efficacy of oral tocolytic therapy. [see comment]. Am J Obstet Gynecol. Oct. 1996;175(4 Pt 1):838-42. [pmid: 8885732].
38 Berkman ND, Thorp JM Jr, Hartmann KE, et al. Management of preterm labor. Evid Rep Technol Assess (Summ ). Oct. 2000;(18):1-6. [pmid: 11127122].
39 Sampson M, McGowan J, Cogo E, et al. An evidence-based practice guideline for the peer review of electronic search strategies. J Clin Epidemiol. Sep. 2009;62(9):944-52. [pmid: 19230612].
40 UpToDate. Available at: http://www.uptodate.com/online/content/search.do. November 29, 2010.
41 Sanchez-Ramos L, Kaunitz AM, Gaudier FL, et al. Efficacy of maintenance therapy after acute tocolysis: a meta-analysis. [see comment]. Am J Obstet Gynecol. Aug. 1999;181(2):484-90. [pmid: 10454704].
42 Thornton JG. Maintenance tocolysis. BJOG. Mar. 1. 2005;112:118-21. [pmid: 15715609].
43 Higgins J, Green S, editors. Cochrane handbook for systematic reviews of interventions. Wiley Online Library. 2008. Chapter 10, Addressing Reporting Biases.
44 Allbert J, Johnson C, Roberts W. Subcutaneous terbutaline tocolysis for recurrent preterm labor via infusion pump. Am J Obstet Gynecol. 1991;164:365.