# Peer Reviewers

Debra Guinn, M.D.

Department of Obstetrics and Gynecology

Northwest Perinatal Centre

Portland, OR

John Morrison, M.D.

Department of Obstetrics and Gynecology

University of Mississippi Medical Centre

Jackson, MS

Hyagriv Simhan, M.D., M.S.C.R.

Department of Obstetrics, Gynecology & Reproductive Sciences

University of Pittsburgh

Pittsburgh, PA

Charles Lockwood, M.D., M.H.C.M.

Department of Obstetrics, Gynecology & Reproductive Sciences

Yale University

New Haven, CT

Katherine Wenstrom, M.D.

Department of Obstetrics and Gynecology

Brown University

Providence, RI

Brian Mercer, M.D.

Department of Reproductive Biology

Case Western Reserve University

Cleveland, OH