# Key Informants

Alan Fleischman, M.D.

March of Dimes Foundation

White Plains, NY

Elizabeth Hill-Karbowski, C.N.M., M.S.N.

St. Joseph's Hospital

Milwaukee, WI

Paul Keenan, M.D.

Oklahoma Health Care Authority

Oklahoma City, OK

Sylvia Lopez, M.D.

Oklahoma Health Care Authority

Oklahoma City, OK

Nancy Jo Reedy, R.N., C.N.M., M.P.H.

Andrews Midwife Center

Fort Worth, TX