# Introduction

Preterm birth continues to be one of the largest contributors to neonatal morbidity and mortality worldwide and is associated with both short- and long-term disability. Preterm birth is defined as delivery before the completion of the 37th week of gestation and affects 12.3 percent of live births in the United States.1 According to the 2010 National Vital Statistics report, there were 542,893 preterm births in the United States in 2006.^2^ Approximately 40 percent of preterm births occur after the spontaneous onset of preterm labor.27 Rates of preterm birth result in a significant disease burden to the health care system. Interestingly, the most recent data suggest a modest decrease in the preterm birth rate.28 When medically indicated preterm births are excluded, the rates of spontaneous labor appear to have fallen by 20 to 30 percent.29 The reasons behind this encouraging improvement deserve further elucidation.

Although overall rates of neonatal mortality are declining, infants born too early continue to be at risk.3 Early preterm deliveries (less than 32 weeks' gestation) comprise 2 percent of all births in the United States, yet 54 percent of all infant mortalities occur in this group.3 Neonatal survival increases steadily with increasing gestational age, particularly prior to 32 weeks' gestation, largely due to advances in neonatal care. Although this improvement is promising, the resulting increase in short- and long-term morbidity and the effect on quality of life for survivors are of concern.

The diagnosis of preterm labor is elusive, largely because the exact sequence and timing of events are poorly described and incompletely understood. This is partly due to the multifactorial nature of preterm labor, which arises from several different pathways but culminates in the same outcome of preterm birth. Further, the symptoms of preterm labor (i.e., pelvic pressure, increased vaginal discharge, backache, and menstrual-like cramping) are often vague. In the past, the presence of regular uterine contractions was sufficient to diagnose preterm labor and much of the literature uses this criterion. Due to the lack of precision involved in diagnosis, up to 40 percent of women with a preterm labor diagnosis are not actually in labor.30 Consequently, a significant proportion of women enrolled in clinical trials of tocolytic efficacy were not destined to deliver preterm.

Currently, most clinicians require appropriate evidence of progressive change in cervical dilation and/or effacement before a diagnosis of preterm labor is made. A diagnosis of preterm labor made based on contraction frequency of ≥ six per hour and cervical dilation ≥ 3 cm and/or effacement ≥ 80 percent, or if membranes rupture or bleeding occurs, is reasonably accurate.31,32 Most clinicians, however, view any documented cervical change accompanied by regular contractions to indicate preterm labor, and intervene before the aforementioned criteria are met. Although doing so results in treatment of more women who are not destined to deliver preterm, early intervention is believed to benefit the infants of women who are experiencing true preterm labor. Documentation of cervical change is thought to increase the sensitivity and specificity of the diagnosis; this may allow for more rigorous evaluation of the effectiveness of treatments for preterm labor and reduce the number of patients treated unnecessarily.

Perinatal morbidity among premature infants can be loosely divided into short-term and long-term sequelae. Short-term outcomes include respiratory distress syndrome, intraventricular hemorrhage, necrotizing enterocolitis, sepsis, hypoglycemia, thermal instability, and jaundice.33 Although these immediate concerns are important and often require treatment in the neonatal intensive care unit (NICU), long-term outcomes determine the overall quality of life for children and their families. These outcomes include bronchopulmonary dysplasia, significant intraventricular hemorrhage (grade III/IV), and retinopathy of prematurity.

Preterm labor is notoriously difficult to treat, owing in large part to the multifactorial nature of the condition. Risk factors for preterm labor include history of preterm birth, multiple gestation, maternal nonwhite race, low socioeconomic status, maternal underweight status, and maternal stress.34-36 Spontaneous preterm labor occurs in the absence of maternal or fetal illness. The ultimate goal of treating preterm labor is to reduce long-term mortality and morbidity of the offspring. Unfortunately, most studies to date have focused on the prevention of preterm birth using surrogate endpoints such as gestational age at delivery, birthweight, and NICU admission.

A tocolytic is a drug used to inhibit contractions and delay the parturitional process. Tocolytic therapy has thus far demonstrated poor efficacy, likely because the parturitional process is already well established. The goals of tocolysis are to reduce neonatal morbidity and mortality without causing significant maternal or neonatal side effects. Tocolytic therapy to date has primarily focused on short-term delay in delivery to allow for maternal administration of corticosteroids and transport to an appropriate facility for neonatal care. The most appropriate measures to assess the efficacy of tocolytic agents should focus on improved health outcomes for infants. To date, most tocolytic trials of maintenance therapy have insufficient power to assess such endpoints.

The majority of tocolytic agents used to inhibit uterine contractions are efficacious for a period of approximately 48 hours. In contrast, terbutaline sulfate has been used in selected patients as maintenance tocolytic therapy to inhibit uterine contractions for longer periods of time after an episode of preterm labor has been arrested acutely with first-line tocolytic agents (including but not limited to indomethacin, magnesium sulfate, nifedipine, and nitroglycerin). Terbutaline is a β-sympathomimetic drug that relaxes smooth muscle in the bronchial tree, blood vessels, and myometrium.4 For maintenance tocolysis, terbutaline is delivered by a subcutaneous (SQ) pump, usually at a basal rate of 0.03–0.05 mg/hr with intermittent boluses of 0.25 mg every 4 to 6 hours.37 As with all other contemporary tocolytics, the use of terbutaline for maintenance tocolysis is off-label. The Food and Drug Administration has approved terbutaline for the management of acute and chronic obstructive pulmonary disease.

Maternal side effects are common because terbutaline does not act on the myometrium alone. Although most side effects are mild and self-limiting, such as shortness of breath, chest pain, anxiety and fatigue,10 serious adverse reactions such as pulmonary edema, myocardial ischemia, cardiac arrhythmias, hypotension, and metabolic alterations may also occur.4

Maintenance tocolytic therapy with a terbutaline pump has been evaluated in two systematic reviews. A Cochrane review concluded that the pump does not decrease the risk of preterm birth by prolonging pregnancy based on two small randomized trials (Guinn n=52 and Wenstrom n=42).4 Further, lack of information on safety and costs to implement therapy do not support use of the pump for the clinical management of arrested preterm labor. Another review included both randomized trials from the Cochrane review and also four additional observational studies.5 Results were contradictory, with randomized trials failing to show efficacy and observational studies demonstrating positive results.

An Agency for Healthcare Research and Quality (AHRQ) review examined the use of β-mimetic agents for maintenance tocolysis.38 No benefits were observed for gestational age at birth, prolongation of pregnancy, or birthweight. In addition, β-mimetics were classified as conferring a high probability of maternal risk, including cardiovascular harms. However, the investigators did not distinguish between first-line and maintenance therapies when assessing harms and the SQ terbutaline pump was not examined specifically.

Despite conflicting evidence from previous systematic reviews, proponents of the terbutaline pump believe it still has a role as a maintenance tocolytic agent in women with arrested preterm labor. Given the discrepancy between available data and clinical practice, AHRQ commissioned a new systematic review of the literature to solidify the benefits and harms of the SQ terbutaline pump for maintenance tocolysis.

In this report we have systematically reviewed and summarized the available literature on the use of terbutaline pump for maintenance tocolytic therapy in women with arrested preterm labor. This evidence report will add to previous systematic reviews by performing an up to date search of the literature, synthesizing evidence in the context of specific populations of women, addressing confounding by level of maternal activity and level of maternal care, and grading the strength of evidence for important outcomes to help decision-makers develop evidence-based recommendations and policies.

A systematic review of terbutaline pump for maintenance tocolysis will inform clinicians, patients, and policymakers about the appropriateness of ongoing use and provide support for clinical guidelines. We hope that this review will result in more safe and effective treatment of women with preterm labor and, ultimately, in a reduction in mortality and long-term morbidity for their offspring.

Based on comments received during the peer-review process, we made modifications to the format of the Key Questions (For details, see Appendix G).

## Conceptual Framework and Key Questions

As shown in the analytic framework (Figure A, Executive Summary), we focused our evidence review on the following six Key Questions.

In women with arrested preterm labor, does treatment with a SQ infusion of terbutaline delivered by a pump, in comparison with placebo, conservative treatment or other interventions:

Key Question 1: improve neonatal health outcomes, including bronchopulmonary dysplasia, neonatal death, death within initial hospitalization, significant intraventricular hemorrhage (grade III/IV), necrotizing enterocolitis, periventricular leukomalacia, retinopathy of prematurity, seizures, sepsis, and stillbirth for the following subgroups:

a. Women <28 weeks, 0 days of gestation (extremely preterm)?
b. Women between 28 weeks, 0 days and 31 weeks, 6 days of gestation (very preterm)?
c. Women between 32 weeks, 0 days and 33 weeks, 6 days of gestation (preterm)?
d. Women between 34 weeks, 0 days and 36 weeks, 6 days of gestation (later preterm)?
e. Multiple gestation?
f. Racial or ethnic subgroups?
g. Women with previous preterm birth?
h. Women with history of preeclampsia?
i. Women with recurrent preterm labor (RPTL) and women without RPTL

Key Question 2: improve other surrogate outcomes, including gestational age at delivery, incidence of delivery at various gestational ages (<28 weeks, < 32 weeks, <34 weeks, <37 weeks), mean prolongation of pregnancy (days), birth weight, ratio of birth weight/gestational age at delivery, pregnancy prolongation index, need for assisted ventilation, need for oxygen per nasal cannula, and NICU admission for the following subgroups:

a. Women <28 weeks, 0 days of gestation (extremely preterm)?
b. Women between 28 weeks, 0 days and 31 weeks, 6 days of gestation (very preterm)?
c. Women between 32 weeks, 0 days and 33 weeks, 6 days of gestation (preterm)?
d. Women between 34 weeks, 0 days and 36 weeks, 6 days of gestation (later preterm)?
e. Multiple gestation?
f. Racial or ethnic subgroups?
g. Women with previous preterm birth?
h. Women with history of preeclampsia?
i. Women with RPTL and women without RPTL

Key Question 3: increase the maternal harms of arrhythmia, heart failure, hyperglycemia, hypokalemia, maternal mortality, myocardial infarction, pulmonary edema, or refractory hypotension, or result in an increased rate of maternal discontinuation of therapy and maternal withdrawal due to adverse effects (withdrawal-AE)?

Key Question 4: increase the neonatal terbutaline-related harms of hypoglycemia, hypocalcemia, and ileus?

Key Question 5: Can the differences in the outcomes above be partially explained by the differences in level of care (e.g., frequency of followup, nurse visits, concomitant treatment, etc.) and level of activity (e.g., other children in the home, marital/support status, working status, bed rest, etc.) between the terbutaline pump group and the comparator group?

Key Question 6: What is the incidence of failure of the pump device used for terbutaline infusion, including missed doses, dislodgment, and overdose?

The report is organized into the following chapters. The Methods chapter describes the review methodology and provides details about topic development, the search strategy, study selection, data extraction, and statistical analyses. The Results chapter provides the results, organized by the six key questions, and a description of the applicability of the body of evidence according to the PICOTS framework. In the Discussion chapter, we provide a discussion to summarize the key findings, enumerate final conclusions, and offer recommendations for future research. Appendixes A and B provide details about the search strategies and grey literature sources respectively. In Appendix C, we list the companies that were sent requests for Scientific Information Packet. Screening, data extraction, risk of bias, and applicability forms are provided in Appendix D. Appendix E provides the citations of excluded studies. Evidence tables with study-level data are presented in Appendix F. Finally, Appendix G describes modifications to the format of the Key Questions subsequent to the peer review process.