# Glossary

Applicability: The relevance of the evidence base to an external population.
Bias: A systematic error, arising from participant selection or outcome measurement that produces an erroneous effect estimate.
Preterm birth: Delivery before completion of the 37th week of gestation.
Strength of evidence: The strength of evidence grading reflects a global assessment of the evidence base. Strength of evidence may be designated as insufficient, low, moderate or high based on the domains of study risk of bias, consistency, directness, and precision.
Tocolytic: An agent that inhibits labor by slowing or halting uterine contractions.