# Discussion

The rate of preterm birth in North America is considerably high at 12.3 percent.1 These births will contribute to the health care burden, including increased short- and long-term neonatal morbidity. An effective and safe intervention to delay or prevent preterm birth would be a welcome addition to the maternity care provider's armamentarium.

To clarify the evidence on the efficacy and safety of subcutaneous terbutaline (SQ terbutaline) infusion by pump for the prevention of preterm birth, the Agency for Healthcare Research and Quality requested an evidence report answering six distinct questions. We applied rigorous selection criteria and assessed risk of bias of each study. This evidence report outlines a comprehensive review of all the available research.

In this final chapter, we first review the limitations of included studies, then the major findings pertaining to each key question and the strength of the evidence for the prespecified outcomes of incidence of delivery at various gestational ages; mean prolongation of pregnancy; bronchopulmonary dysplasia; significant intraventricular hemorrhage (grade III/IV); neonatal death and/or death within initial hospitalization; and maternal withdrawal due to adverse effects (Withdrawal-AE). We graded the strength of evidence based on the domains of overall risk of bias, consistency, directness, and precision. We then present our conclusions, make recommendations for future research, and offer clinical and public health perspectives.

## Limitations of Included Studies

Studies contributing evidence were either absent or sparse for most outcomes. Although evidence from randomized controlled trials (RCTs) pertained to women with preterm labor, the specific populations of investigational interest were not distinguished. Furthermore, the two trials were clearly underpowered for outcomes of benefit and harms. Evidence pertaining to specific populations of women with preterm labor originated in observational studies of medium to high risk of bias. Across several studies, our concern that participants might have been double-counted because a common database was used could not be ruled out. Baseline clinical and socioeconomic characteristics with important prognostic implications were not reported across all studies. For example, no studies presented data on concomitant medications, body mass index, history of preeclampsia, cervical position, cervical consistency, cervical station, Bishop's Score, or fetal fibronectin. Cointerventions, such as administration of corticosteroids, were rarely described. None of the included studies assessed long-term childhood outcomes, such as childhood development, neurobehavioral testing, long-term lung function, and long-term vision.

In completing this review, we undertook an extensive grey literature search. Further, we requested relevant scientific information from the industry, Matria (now called Alere) Healthcare, and had many experts in the field participate in the review process. Despite this thorough process, the number of identified studies was very small—we had too few studies per outcome to perform statistical assessment of publication bias. We believe that all relevant data regarding the use of subcutaneous terbutaline for the prevention of preterm labor is captured in this review. Any exaggerated positive findings are more likely due to the medium to high risk of bias detected in observational studies than publication bias.

## Summary of Key Findings

### Key Question 1 Neonatal Health Outcomes

Information regarding neonatal health outcomes is derived from a few underpowered studies that examine the effect of SQ terbutaline infusion for the prevention of preterm birth on the key predictors of long-term health sequelae for offspring. The outcomes assessed in this review include those neonatal conditions that are generally accepted to be associated with mortality or impaired function later in life. Studies were either absent or underpowered for outcomes such as bronchopulmonary dysplasia, intraventricular hemorrhage, necrotizing enterocolitis, retinopathy of prematurity, sepsis, stillbirth, periventricular leukomalacia, and seizures, thereby limiting the utility of the data. Strength of evidence is insufficient for bronchopulmonary dysplasia and significant intraventricular hemorrhage.

Neonatal death was assessed using two different outcomes: classic neonatal death (i.e., death within the first 28 days of life) and death within initial hospitalization. Death within initial hospitalization is important given that the topic of interest is preterm birth—risk of morbidity and mortality in this population may extend beyond the first 28 days of life. However, no studies examined this variable and strength of evidence for this outcome, therefore, is insufficient. For neonatal death, strength of evidence favoring the SQ terbutaline pump over maintenance oral tocolytic therapy (92.3% received oral terbutaline) is low for women with recurrent preterm labor (RPTL) and twin gestation based on a single study from the Matria database (odds ratio [OR] = 0.09, 95% confidence interval [CI]: 0.01, 0.70). While this result is striking in the presence of insufficient findings on other neonatal health outcomes reported above, it is apparent that it stems from the largest of studies contributing data on neonatal health outcomes with over 700 patients. As such, it is the only outcome that appears to be adequately powered to reach statistical significance. For other populations of pregnant women with arrested preterm labor, the evidence was graded insufficient.

### Key Question 2 Other Surrogate Outcomes

Surrogate outcomes are commonly used in maintenance tocolytic trials to assess efficacy. For many of these outcomes we could not assess data for important populations (as it was not reported), including delivery <28 weeks, specific gestational ages, racial or ethnic subgroups, women with previous preterm birth, or women with a history of preeclampsia.

A common outcome used in tocolytic trials of maintenance therapy is the incidence of delivery at various gestational ages. We chose to group gestational age at delivery according to commonly accepted categories of <28 weeks, <32 weeks, <34 weeks and <37 weeks, which correlate with improvements in clinical outcomes. Under this Key Question, we graded the strength of evidence for incidence of delivery at each gestational age cut-point and mean prolongation of pregnancy for prespecified populations. The strength of evidence for incidence of delivery at <28 and <34 weeks is insufficient. However, for the other outcomes strength of evidence favoring pump over oral tocolytics or no treatment is generally low for women with twin gestation and/or RPTL.

Mean birth weight significantly increased with the SQ terbutaline pump compared with oral tocolytics or no treatment in women with twin gestation and/or RPTL. This evidence largely originated from observational studies that used the same Matria database. Therefore, the studies were at risk of double-counting of participants across them. Two RCTs, which did not pertain to any specific population of interest, reported statistically nonsignificant differences between SQ terbutaline pump and placebo. However, this result is inconclusive because of the possibility of type II error. The RCT evidence contrasted with results from larger cohort studies, which demonstrated consistent benefit.

The final group of surrogate outcomes that were assessed involved need for specialized neonatal care. For women with twin gestation and/or RPTL, evidence from observational studies, mostly from the Matria database, showed lower incidence of neonatal intensive care unit (NICU) admission and shorter duration of stay for infants whose mothers used SQ terbutaline pump (incidence of NICU admission: OR range 0.28–0.72, 95% CI range: 0.08–0.58, 0.63–0.97 and NICU mean length of stay: range of mean difference in days: -3.50 to -17.90, 95% CI range: - 5.26 to -32.88, -1.74 to -3.54). One retrospective cohort in women with RPTL showed a nonsignificant decrease in the need for assisted ventilation among infants of the SQ terbutaline pump group.18 No data were available on need for oxygen per nasal cannula.

### Key Question 3 Maternal Harms

The data available on incidence of maternal harms are sparse. One small prospective cohort showed a significant increase in tachycardia/nervousness among women using SQ terbutaline pump (OR = 25.48, 95% CI 1.23, 526.64).13 In one RCT of terbutaline infusion versus placebo, 45.8 percent of patients discontinued the terbutaline infusion compared to 32 percent of patients who discontinued placebo treatment.10 The available data does not suggest the reasons for discontinuation of therapy (e.g., inconvenience versus nuisance side effects versus major complications).

Results for the outcomes of maternal mortality, pulmonary edema, maternal hyperglycemia, and therapy discontinuation were inconclusive because studies were not adequately powered to detect these rare findings. No data were available for several recognized adverse outcomes, including hypokalemia, refractory hypotension, heart failure, myocardial infarction, and study withdrawal due to adverse effects (strength of evidence is insufficient).

The Food and Drug Administration (FDA) has issued new warnings against the use of terbutaline in pregnant women for prevention or prolonged treatment (beyond 48 to 72 hours) of preterm labor. 24 Based on postmarketing reports of maternal deaths and serious cardiovascular adverse events associated with the obstetrical use of terbutaline, the FDA is requiring that a Boxed Warning and Contraindication be placed on injectable and oral terbutaline drug labels. Between 1976 and 2009, 16 maternal deaths were reported; at least three of these cases were clearly reported to be in association with the administration of SQ terbutaline pump. Between 1998 and 2009, 12 maternal cases of serious cardiovascular events were reported, including arrhythmias, myocardial infarction, pulmonary edema, hypertension and tachycardia; at least three of these cases were clearly reported to be in association with the administration of the SQ terbutaline pump.24 Although meriting transparent disclosure in the form of a warning, evidence emerging from case reports is usually regarded as noncomparative and a hypothesis generating signal rather than a hypothesis testing confirmation.25 Furthermore, case reports are useful in identifying rare and unexpected adverse events—the rarer the adverse event, the stronger the effect size, and the magnitude of effect size is an important criterion that increases our confidence in an estimate.9 However, adverse events such as death, hypertension, tachycardia, arrhythmias, and pulmonary edema that were reported with the use of terbutaline are not so unexpected in any adult population—pregnant women may experience these adverse events in the absence of terbutaline therapy due to other reasons.

### Key Question 4 Neonatal Harms

Neonatal harms data were also very sparse. In one small RCT, only one case of hypoglycemia was identified in an infant whose mother received placebo infusion.11 Given such a small event rate, the utility of this information is limited by insufficient power. No data were available for the incidence of neonatal hypocalcemia or ileus.

### Key Question 5 Level of Activity and Level of Care

Differences in maternal activity and level of care could potentially explain differences in outcomes. Level of activity was rated as low, normal, or high based on a composite assessment of the following variables: marital status, working status, caring for other children in the home, available social support, bed rest, and restriction of maternal activities. Level of care was rated as low, moderate, or high based on the following variables: nursing assessments, home uterine activity monitoring, home visits, education about preterm labor, telephone support, restriction of maternal activities, and other cointerventions. Unfortunately, few studies reported these as study level covariates, which precluded statistical assessment of heterogeneity by meta-regression. Furthermore, a qualitative assessment of heterogeneity revealed no apparent trends.

### Key Question 6 Incidence of Pump Failure

SQ terbutaline is administered by a mechanical pump, and, therefore, it is important to consider possible technology-related issues. Although the Key Question only specified missed doses, dislodgment, and overdose, we investigated a wider range of pump-related problems, including pump malfunction and local pain or skin irritation. No study reported on outcomes of missed doses or overdose. One case series reported a 2 percent incidence of dislodgement of the SQ catheter.22 The same series reported a 2 percent incidence of unspecified pump malfunction. One small RCT reported the side effects of local pain and skin irritation, which were present in less than 20 percent of patients and not statistically different in patients receiving terbutaline infusion compared to a placebo pump.11 No infusion site infections were reported in another case series.23 Although these studies do not suggest that pump-related complications are significant, adverse events related to the pump device should be documented in future studies.

## Conclusions

The available evidence for the SQ terbutaline pump as maintenance tocolytic therapy in women with arrested preterm labor pertained to only two of the specific populations of interest: women primarily with singleton gestation and RPTL or those with twin gestation and RPTL. This evidence base came entirely from observational studies, and most studies (45 percent) originated from a single proprietary database. The available RCT evidence did not apply to any of the specific preterm populations described in Key Questions 1 and 2, but rather included nonspecific populations of women with preterm labor.

For neonatal death, the strength of evidence favoring SQ terbutaline pump therapy compared with oral tocolytics is low for women with twin gestation and RPTL (OR=0.09, 95% CI: 0.01, 0.70). Strength of evidence favoring the terbutaline pump compared to oral tocolytics or no treatment is also low for the surrogate outcomes of pregnancy prolongation in women with twin gestation and/or RPTL. Insufficient evidence addressed bronchopulmonary dysplasia, death within initial hospitalization, significant intraventricular hemorrhage, and maternal withdrawal due to adverse events. The strength of evidence for nonspecific populations of women with preterm labor described in RCTs is insufficient.

Scant and underpowered evidence demonstrated inconclusive results for all other neonatal health outcomes, neonatal harms, maternal harms, and pump-related outcomes. Observational studies of medium to high risk of bias, with potential for participant double-counting, showed the benefit of the SQ terbutaline pump compared with oral tocolytics for other surrogate outcomes, such as birth weight and NICU admission.

FDA postmarketing surveillance has detected maternal deaths and maternal cardiovascular events in association with terbutaline tocolysis in general, and pump therapy in particular. However, causal association cannot be established with this evidence.

In conclusion, although evidence suggests that pump therapy is beneficial as maintenance tocolysis, our confidence in the validity and reproducibility of this evidence is low. While postmarketing surveillance has detected cases of serious harms, the safety of the therapy remains unclear.

### Comparison of Results With Other Systematic Reviews

In agreement with the review by Nanda et al., we found that the available RCT evidence showed nonsignificant differences between the SQ terbutaline pump and placebo or oral terbutaline for several outcomes.4 Nanda et al. concluded, “Terbutaline pump maintenance therapy has not been shown to decrease the risk of preterm birth by prolonging pregnancy” (p.2). The review also commented on the lack of information regarding safety and advocated for further study. We agree with these conclusions, but would also emphasize that the RCT evidence was likely prone to type II error.

The Hayes group conducted a systematic review of the SQ terbutaline pump for maintenance therapy and, in contrast to the review by Nanda et al., included both observational studies and RCTs.5 This review found that the available RCT and observational evidence was conflicting and our review came to a similar conclusion; RCT evidence did not demonstrate benefit of the SQ terbutaline pump, although cohort studies of limited methodological validity demonstrated statistically significant effects in favor of the pump for several outcomes. Our review included some additional studies that were not part of the Hayes review because we performed a more recent search, we did not have a lower cutoff year, and we included case series to assess pump-related outcomes. Furthermore, the Hayes review did not specifically investigate different populations, the effect of confounding by level of maternal activity or level of maternal care, or pump-related outcomes. Our review examined these additional factors but found only limited data to address them. We also graded the strength of evidence from the body of observational studies as mostly insufficient or low for women with twin gestation and/or RPTL.

## Applicability

Below we summarize characteristics of applicability based on the domains of population, intervention, comparator, outcome, and setting. The following factors should be considered by maternity care providers and policymakers when entertaining the option of recommending the SQ terbutaline pump to women with preterm labor.

Nine of 14 studies (64 percent) included women judged to be in labor on account of persistent contractions and cervical change. The definition of labor was unclear in other studies. Among the evidence that suggested that the pump was efficacious, 50 percent reported cervical change and contractions as part of the definition of labor, and 50 percent did not report how labor was defined.

The majority of evidence included women with RPTL (i.e., treated with first-line tocolytic therapy for 48 hours, have cessation of symptoms, and then present with a second episode) and singleton gestation. Some evidence pertained additionally to women with twin gestation and RPTL, which is a high-risk, specialized group of patients.

Several studies included patients from a national proprietary database run by Matria (now called Alere) Healthcare, which provides an outpatient perinatal program consisting of 24-hour nursing and pharmacy support, home uterine activity monitoring, individualized education, and provision of tocolytic therapy to women with preterm labor. These women generally received a high level of care based on nursing assessments, home uterine activity monitoring, home visits, education about preterm labor, telephone support, restriction of maternal activities, and other cointerventions. The distribution of regions from which patients were recruited into the national database is unknown. Further, it is impossible to make any judgments about the standards followed by the individual practice sites that were providing obstetrical care to the women in the database.

In general, the dose and duration of SQ terbutaline pump therapy were typical of those used in clinical practice, although some studies did not provide adequate information regarding basal and bolus doses to allow assessment. Level of care and training provided to patients on pump were also typical in most studies, although this information was also somewhat limited. In several studies, patients received specialized outpatient support in the form of nursing/pharmacy support, monitoring and contact with physicians; this level of care may not be typical of practice. Investigators typically did not report information on cointerventions, such as bed rest, restriction of maternal activities, and administration of corticosteroids.

Multiple comparison groups were used, including no treatment, placebo, and oral tocolytics.

Outcomes most commonly reported in the literature were surrogates, such as gestational age at birth, prolongation of pregnancy, and birth weight. Data on clinical outcomes and neonatal/maternal harms, including pump-related outcomes, are sparse. Several important clinical outcomes have not been investigated. These include short-term outcomes of neonatal death within initial hospitalization, intraventricular hemorrhage, and bronchopulmonary dysplasia and long-term outcomes, such as developmental and neurobehavioral testing.

No long-term outcomes of the SQ terbutaline pump for maintenance tocolysis have been assessed. This absence of followup beyond delivery is a major limitation of the available evidence.

## Future Research

Although cohort studies have provided a glimpse of the potential for SQ terbutaline pump to improve short-term neonatal outcomes for fetuses at risk for preterm birth, the answers to several important questions remain unanswered. Most importantly, it remains to be seen whether SQ terbutaline pump therapy alters long-term development or systemic impairment of offspring, and neonatal/maternal morbidity and mortality. The limitations of the available data must also be recognized. Most of the cohort studies were medium to high risk of bias. In addition, several of the cohort studies investigated participants from a single proprietary database (Matria), which raises concerns regarding double-counting of patients and common biases. Therefore, results showing effectiveness should be interpreted with caution, especially in light of the recent FDA warnings.

Information is lacking on the effectiveness and safety of the SQ terbutaline pump as a maintenance tocolytic treatment in specific populations, including women who deliver at specific gestational ages, women of different racial or ethnic backgrounds, and women with previous preterm birth or preeclampsia. Future studies, whether observational or experimental in design, should focus on garnering evidence for these specific populations.

Below we provide some specific recommendations for the conduct of RCTs and observational studies to further elucidate the potential benefits and harms of SQ terbutaline pump for maintenance tocolysis.

### Randomized Trials

We recommend that an adequately powered randomized controlled and pragmatic clinical trial that assesses the SQ terbutaline pump as a maintenance tocolytic be conducted. A pragmatic RCT is designed to have broad applicability so that the results can guide decisions about practice.26 Such a trial should be placebo controlled and include blinding of study participants, care providers, and study personnel. Consideration should be given to employing multiple treatment arms in order to evaluate the pump against other tocolytic agents and conservative management. Furthermore, the level of care provided to participants (i.e., nursing assessments, home uterine monitoring, education, telephone support, and restriction of activities) should be practical, feasible, and likely to be adopted in routine practice. Important cointerventions, such as administration of corticosteroids, should be reported. A full accounting of the number of women approached but not enrolled should be included to allow users to assess the impact of respondent bias. The analysis should be “intent to treat,” where all participants assigned by randomization to each group are included in the primary comparisons, regardless of whether the assigned medication was received. Outcomes to be examined should go beyond those of prolongation of pregnancy and birthweight to hard clinical endpoints of neonatal morbidity, such as bronchopulmonary dysplasia, necrotizing enterocolitis, significant intraventricular hemorrhage (grade III/IV), retinopathy of prematurity, sepsis, stillbirth, and neonatal death. Lastly, there should be long-term followup to assess subsequent childhood outcomes. Pharmacodynamic and pharmacokinetic outcome measures can additionally be studied to understand inter-individual differences in effectiveness and toxicity and avoidance of β-agonist related tachyphylaxis.

Conducting such RCTs to assess the efficacy of tocolytics in general is notoriously difficult. A definitive trial in this domain must include a focus on accurate diagnosis of preterm labor (perhaps combining stringent clinical criteria with factors such as positive fetal fibronectin and shortened transvaginal cervical length). Emphasis must also be placed on securing funding and maintaining followup for an appropriate duration of time to allow assessment of long-term childhood outcomes, including neurobehavioral testing and developmental assessment.

### Observational Studies

Although the RCT is the ideal study design for evaluating the efficacy of interventions, at times it may not be considered feasible for a number of reasons, such as a prohibitive sample size requirement and ethical considerations. We realize that collecting RCT evidence on clinically important outcomes may not be possible because a large number of patients will need to be recruited to detect rare events, such as maternal deaths. Therefore, we additionally propose:

- Well-designed, well-powered cohort studies examining clinical outcomes. These studies should include a representative and inception cohort of all patients with arrested preterm labor. Since observational studies are susceptible to the effects of confounding, future observational studies should measure, report, and adjust for potential confounders such as fetal fibronectin, cervical length/dilation, cerclage, maternal characteristics (e.g. age, race), level of care and activity, and concomitant medications; propensity scores based on these variables may be considered. Other considerations about power, multiple comparison groups, level of care, reporting of cointerventions, and long-term followup are the same as for RCTs.
- Record linkage studies in which mother's prenatal, and infants NICU and childhood developmental electronic health records are linked may be a more practical research proposition for the near future with improvements in quality and accessibility of electronic patient records. NICU registries in which prenatal data of mothers are available can be very valuable source. However, such linkage based studies may also be impacted by biases not uncommon to cohort study designs, especially confounding because of unmeasured or unrecorded variables with important prognostic implications.

## Implications

Given the sparse evidence favoring SQ terbutaline pump therapy over other tocolytics or no treatment, we have low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.9 Therefore, this systematic review calls into question the evidence base for the current practice of using terbutaline pump as a maintenance tocolytic agent. Decisionmakers and policymakers should take into consideration the limitations of the available data when formulating recommendations.

Most of the available data are surrogate outcomes of preterm labor. Although many decisions regarding the SQ terbutaline pump are currently made on the assumption that short-term outcomes (for example, a heavier neonate or an infant born beyond 32 weeks) will correlate well with improved long-term outcomes, rigorous scientific evaluation is needed to confirm whether such factors do, in fact, lead to better outcomes in this population. As with any intervention, the benefits of providing treatment at varying gestational ages should outweigh the risks associated with the intervention. Given the sparse epidemiological and trial evidence available on maternal and neonatal harms and the recent FDA warning against the use of terbutaline for tocolysis based on case reports of maternal deaths and serious cardiovascular events, further discussion among policymakers and health care providers is urgently needed to determine if the risks and costs of SQ terbutaline infusion by pump are justified in this vulnerable population.