# Modifications to Key Questions

Based on comments received during the peer-review process, we made modifications to the format of the Key Questions, as described below:

- The ordering of outcomes within each Key Question
- The format of definitions for extremely preterm, very preterm, preterm, and later preterm (e.g., modification from women between 28 +0 and 31 +6 weeks of gestation to women between 28 weeks, 0 days and 31 weeks, 6 days of gestation)
- Addition of the word “ethnic” to subgroup f
- Addition of the word “surrogate” to Key Question 2
- WDAE changed to Withdrawal-AE in Key Question 3
- Addition of the term “terbutaline-related” harms to Key Question 4