# Evidence Tables

Table F1 Detailed study-level characteristics

Study Identification | Study Population | Definition of Preterm Labor | Comparison Group (N): Mean Daily Dose ± SD (mg) Intervention Group (N): Mean Daily Dose ± SD (mg) | Overall Risk of Bias With Explanation (rating applies to all outcomes unless specified otherwise)
First Author (year): Guinn (1998)^9^ Design: RCT Setting: Birmingham Hospital, Alabama (Nov 1994–Apr 1997) Funding Source: MiniMed Technologies (supported in part) | n = 52 Mean Maternal Age ± SD (years): 21.6 ± 5.7 Mean Gestational Age ± SD (weeks): 30.6 ± 2.8 (T) Gestation: singletons Primary Tocolytic Treatment: Magnesium sulfate (IV) (with or without indomethacin) Previous Maintenance Tocolytics: NR Inclusion Criteria: Singleton gestation; intact membranes; between 22 and 33^6/7^ weeks gestation; received parenteral magnesium sulfate therapy (with or without indomethacin); arrested preterm labor (<4 contractions/h for ≥ 24 hours) Exclusion Criteria: Contraindication to tocolysis; persistent maternal tachycardia (>120 beats/min); history of cardiac arrhythmia; history of pulmonary edema; uncontrolled diabetes; suspected chorioamnionitis | Uterine contractions > 4 per hour and greater than or equal to one of the following: ≥ 1 cm cervical dilation, ≥ 80% cervical effacement, and documented cervical change. | C: Placebo (saline pump) (28): NA I: SQ terbutaline (24): NR | Low The comparability of groups cannot be assessed for certain because information on all relevant factors has not been presented (e.g., prognostic factors, such as cervical length and fetal fibronectin). However, randomization was carried out properly and patients/health care providers were blinded to treatment allocation, which will limit selection and detection biases.
First Author (year): Wenstrom (1997)^10^ Design: RCT Setting: University of Iowa Hospital (Jan 1990–Apr 1994) Funding Source: NR Companion Article: 43 | n = 42 Mean Maternal Age ± SD (years): 26.2 ± 5.3 Mean Gestational Age ± SD (weeks): 30.4 ± 2.3 (T) Gestation: singletons or twins Primary Tocolytic Treatment: Magnesium sulfate (IV) (if magnesium was insufficient, indomethacin (PO) was administered) Previous Maintenance Tocolytics: NR Inclusion Criteria: Diagnosis of preterm labor Exclusion Criteria: Contraindication to beta-mimetic therapy (i.e. heart disease, insulin-dependent diabetes mellitus, intolerance to terbutaline) or to continued tocolysis in general; cervical dilation > 4 cm | Regular, persistent uterine contractions that produce cervical change in gravidas ≥ 20 weeks and < 35 weeks. | C_1_: Placebo (saline pump) (12): NA C_2_: Oral terbutaline (15): NR I: SQ terbutaline (15): NR | High (oral terbutaline arm) High (placebo arm) Placebo arm: The sample likely represents a very select group, since >90% of eligible subjects declined to participate. The study is likely to be underpowered. There is evidence that randomization was carried out properly, but blinding was not that effective. Missing information makes it difficult to judge comparability of groups in baseline characteristics and prognostic factors, primary tocolytic therapy, and level of care. Oral terbutaline arm: Same as above, except for complete absence of blinding.
First Author (year): Lindenbaum (1992)^11^‡ Design: Nonrandomized trial Setting: Hospital of the University of Pennsylvania (NR) Funding Source: NR | n = 91 Mean Maternal Age ± SD (years): 32.4 ± 2.7 Mean Gestational Age ± SD (weeks): 29.1 ± 1.7 (T) Gestation: singletons Primary Tocolytic Treatment: Magnesium sulfate (IV) or Ritodrine (IV) (other agents may have been administered as well) Previous Maintenance Tocolytics: NR Inclusion Criteria: Women 26–36 weeks' gestation; diagnosis of preterm labor; admitted to labor floor of hospital; normal 1-hour oral glucose tolerance test between 24-28 weeks' gestation Exclusion Criteria: History of pregestational or gestational diabetes; macrosomia; current steroid therapy; multiple gestation | Documented cervical change or uterine contractions ≥ 6 per hour that was unresponsive to bed rest and intravenous hydration. | C: Oral Terbutaline (54): 30 ± NR I: SQ terbutaline (37): NR | High (birth weight and gestational age at delivery) Medium (maternal hyperglycemia) Primary flaw in this study is the difference in groups with respect to severity/prognosis (i.e., groups were divided based on length of primary tocolytic treatment). Also, comparability of groups cannot be assessed due to missing information. The potential difference in severity/prognosis among treatment and comparison groups should not impact the outcome of maternal hyperglycemia. However, issues pertaining to missing information still remain.
First Author (year): Morrison (2003)^12^ Design: Prospective Cohort Setting: NR (Jan 2001–Dec 2001) Funding Source: NR | n = 60 Mean Maternal Age ± SD (years): 25.6 ± 5.2 Mean Gestational Age ± SD (weeks): 29.5 ± 2.3 (P) Gestation: singletons Primary Tocolytic Treatment: Magnesium sulfate (IV) (If magnesium was insufficient, indomethacin (PR) or nifedipine (PO) was administered.) Previous Maintenance Tocolytics: NR Inclusion Criteria: Two or more episodes of preterm labor; stabilized in hospital with IV tocolytics Exclusion Criteria: Further continuation of pregnancy contraindicated (hypertension, fetal distress, intrauterine growth restriction, severe vaginal bleeding); insulin-dependent diabetes; preterm premature rupture of membranes; allergy to beta-sympathomimetic drugs; fetal anomalies; fetal death | Persistent uterine contractions (>12 per hour), cervical change in dilation, and effacement since first episode of PTL. | C: No Treatment (45): NA I: SQ terbutaline (15): NR | High Primary flaw with this study is that there is evidence that groups were not comparable (with respect to risk factors for preterm birth, primary tocolytic therapy, level of care).
First Author (year): Morrison (1992)^13^ Design: Prospective Cohort Setting: NR Funding Source: Vicksburg Hospital Medical Foundation (supported in part) | n = 69 Mean Maternal Age ± SD (years): 28.6 ± 4.7 Mean Gestational Age ± SD (weeks): NR Gestation: Not specified (likely included a mixture of women with single and multiple gestation) Primary Tocolytic Treatment: NR Previous Maintenance Tocolytics: Oral tocolytics (NR) (only received by terbutaline pump group) Inclusion Criteria: Treated with IV tocolysis for documented preterm labor; subcutaneous terbutaline group had failed maintenance oral tocolytic therapy (had RPTL) Exclusion Criteria: Preterm rupture of membranes; agent discontinued due to failure of tocolysis or advanced cervical dilatation at < 37 weeks; scheduled cesarean deliveries; early delivery for obstetric/medical indications | Regular, persistent uterine contractions (usually > 12/hr) with associated cervical change from the previous exam or a change in cervical status with regular contractions, or contractions plus an initial cervical examination ≥ 2 cm | C: Oral tocolytics - ritodrine or terbutaline (41): NR I: SQ terbutaline (28): NR | High Major flaw is that the subcutaneous pump group had RPTL and comparison group did not. Therefore, the intervention group may have had a more serious condition. Also, there is missing information, which makes it difficult to assess other potential limitations.
First Author (year): Flick (2010)^14^ Design: Retrospective cohort Setting: Throughout United States (Matria database) Funding Source: NR | n = 1366 Mean Maternal Age ± SD (years): 28.7 ± 6.1 Mean Gestational Age ± SD (weeks): 30.6 ± 2.9 (P) Gestation: singletons Primary Tocolytic Treatment: NR Previous Maintenance Tocolytics: Oral nifedipine mean daily dose ± SD (mg): 58.5 ± 26.5 Inclusion Criteria: Singleton gestation; < than 35 weeks gestation; referred for hospitalization due to RPTL; prescribed oral nifedipine for maintenance tocolysis; hospitalized for a minimum of 24 hours; received preterm labor treatment; intact membranes; subsequently discharged to resume outpatient services with oral nifedipine or continuous subcutaneous terbutaline infusion Exclusion Criteria: Delivered upon hospitalization; ruptured membranes; > 35 weeks gestation when hospitalized; did not resume outpatient services | NR | C: Oral Nifedipine (830): NR I: SQ terbutaline (536): NR | High Primary flaw is that groups were not similar in baseline characteristics and prognostic factors (i.e., differed in smoking status). Also, missing information makes it difficult to assess similarity of groups with respect to other factors.
First Author (year): de la Torre (2008)^15^ Design: Retrospective Cohort Setting: Throughout United States (Matria database) Funding Source: NR | n = 656 Mean Maternal Age ± SD (years): 30.3 ± 5.8 Mean Gestational Age ± SD (weeks): 30.1 ± 2.9 (P) Gestation: twins Primary Tocolytic Treatment: NR Previous Maintenance Tocolytics: Oral Nifedipine mean daily dose ± SD (mg): 62.3 ± 26.9 Inclusion Criteria: Twin gestation; prescribed oral nifedipine as maintenance tocolysis after an initial episode of preterm labor; hospitalized at <35 weeks gestation for RPTL; at least a 24 hour hospital stay Exclusion Criteria: Delivered within 48 hours of hospitalization; did not resume maintenance tocolysis; ruptured membranes; referred for hospital evaluation but not admitted | Uterine activity above 4–6 contractions per hour or maternal reports of persistent pelvic pressure, cramping, backache, or increased vaginal discharge. | C: Oral Nifedipine (418): 73.7 ± 23.4 I: SQ terbutaline (238): NR | Medium There is a lot of missing information, which makes it difficult to assess comparability of groups (in terms of baseline characteristics and prognostic factors, primary tocolytic therapy, and compliance). But difficult to say that there is any limitation that would invalidate the results for sure.
First Author (year): Fleming (2004)^16^ Design: Retrospective cohort Setting: Throughout United States (Matria database) (Jun 1992–Jun 2000) Funding Source: NR | n = 284 Mean Maternal Age ± SD (years): NR Mean Gestational Age ± SD (weeks): 30.4 ± 2.6 (P) Gestation: singletons Primary Tocolytic Treatment: NR Previous Maintenance Tocolytics: Oral Nifedipine Inclusion Criteria: singleton gestation; prescribed nifedipine following an initial episode of preterm labor; subsequent hospitalization for RPTL at <34 weeks; stabilized by tocolysis per attending physician's plan of treatment; outpatient tocolysis resumed with nifedipine or continuous subcutaneous terbutaline Exclusion Criteria: subjects who could not be matched by gestational age | NR | C: Oral nifedipine (142): 66.7 ± 37.1 I: SQ terbutaline (142): 3.2 ± 1.6 | Medium There is considerable missing information, which makes it difficult to assess the comparability of groups. There is some indication that there are baseline differences (i.e., in age and marital status) and data on many other important factors have not been reported (e.g., cervical length, race, SES). However, there are no major flaws that can be singled out as invalidating the results.
First Author (year): Lam (2003)^17^ Design: Retrospective Cohort Setting: Throughout United States (Matria database) (Apr 1995 – Jan 1999) Funding Source: NR | n = 558 Mean Maternal Age ± SD (years): 27.4 ± 5.9 Mean Gestational Age ± SD (weeks): 31.6 ± 2.2 (P) Gestation: singletons Primary Tocolytic Treatment: NR Previous Maintenance Tocolytics: NR Inclusion Criteria: Singleton gestation; initial episode of preterm labor at > 20 weeks; subsequent hospitalization for RPTL < 35 weeks; stabilized and discharged home following RPTL Exclusion Criteria: Not prescribed tocolytics; lost to followup; medically indicated delivery | NR | C: Oral tocolytics (95.3% received oral terbutaline) (279): mean oral terbutaline dose 24.0 ± 9.3 I: SQ terbutaline (279): 3.5 ± 1.1 | High Primary flaw is that groups were not similar at baseline (differed in smoking status and previous PTD). Also, missing data makes it difficult to assess several other potential limitations.
First Author (year): Lam (2001)^18^ Design: Retrospective Cohort Setting: Throughout United States (Matria database) (Jan 1992 – Jul 1998) Funding Source: NR | n = 706 Mean Maternal Age ± SD (years): 28.8 ± 5.5 Mean Gestational Age ± SD (weeks): 31.3 ± 2.3 (P) Gestation: twins Primary Tocolytic Treatment: NR Previous Maintenance Tocolytics: NR Inclusion Criteria: Twin gestation; initial episode of preterm labor which was treated with oral tocolysis; hospitalized for RPTL at < 35 weeks gestation; stabilized on an inpatient basis for RPTL and then discharged to outpatient services Exclusion Criteria: Delivered after RPTL; remained hospitalized; discharged from outpatient services | NR | C: Oral tocolytics (92.3% received oral terbutaline) (353): mean oral terbutaline dose 25.6 ± 10.4 I: SQ terbutaline (353): 3.9 ± 1.4 | Medium There is a large amount of missing information, which makes it difficult to assess the comparability of groups and other potential limitations. But there are no major flaws that can be identified that would invalidate the results.
First Author (year): Allbert (1994)^19^ Design: Retrospective Cohort Setting: NR Funding Source: Vicksburg Hospital Medical Foundation (supported in part) Companion Article:42 | n = 64 Mean Maternal Age ± SD (years): 27.5 ± 4.3 Mean Gestational Age ± SD (weeks): 32.2 ± 2.7 (T) Gestation: Not specified (likely included a mixture of women with single and multiple gestation) Primary Tocolytic Treatment: NR Previous Maintenance Tocolytics: NR Inclusion Criteria: Documented RPTL; at 20–34 weeks' gestation; between the ages of 15 and 45 years Exclusion Criteria: Continuation of pregnancy contraindicated (fetal distress, chorioamnionitis, intrauterine growth retardation, abruption, preeclampsia, etc.); insulin-dependent diabetes mellitus; allergy to beta-sympathomimetic drugs; premature rupture of membranes; cardiac arrhythmia; significant hemorrhage; fetal anomalies; fetal demise | Persistent uterine contractions and progressive cervical change. | C: Oral terbutaline (32): NR I: SQ terbutaline (32): NR | Medium There is a lot of missing information, which makes it difficult to assess comparability among groups and whether groups were derived from the same population. There is a possibility that groups received a different level of care, since only the subcutaneous terbutaline group has been specified as receiving home nursing care. However, it is unclear if this factor alone would be sufficient to impact the results to a large extent.
First Author (year): Regenstein (1993)^20^‡ Design: Retrospective cohort Setting: NR (Dec 1986–Jan 1992) Funding Source: National Institutes of Health Training | n = 69 Mean Maternal Age ± SD (years): 31.4 ± 5.9 Mean Gestational Age ± SD (weeks): NR Gestation: Not specified (included a mixture of women with single and multiple gestation) Primary Tocolytic Treatment: NR Previous Maintenance Tocolytics: NR Inclusion Criteria: Neceiving home nursing care or care by perinatology service; gestational diabetes screening performed after initiation of chronic terbutaline tocolysis Exclusion Criteria: NR | NR | C: Oral terbutaline (38): 25.9 ± 11.2 I: SQ terbutaline (31): 2.5 ± 1.0 | High Although the harm outcome of maternal hyperglycemia was defined and collected actively, the primary flaw with this study is that groups were not similar in baseline characteristics (i.e., in race and family history of gestational diabetes). Also, since no methods were used to control for confounders, there is a high likelihood that groups may differ in other baseline characteristics and prognostic factors, which have not been reported. There is also a lot of missing information which makes it difficult to assess the comparability of groups (e.g., primary tocolytic, loss to followup, differential level of care, compliance).
First Author (year): Adkins (1993)^21^ Design: Case Series Setting: An urban obstetrics and gynecology group practice, Tennessee (Nov 1989–Feb 1991) Funding Source: PharmaThera Inc. | n = 51 Mean Maternal Age ± SD (years): 31.0 ± 4.0 Mean Gestational Age ± SD (weeks): 29.1 ± 3.6 (T) Gestation: singletons or twins Primary Tocolytic Treatment: Magnesium sulfate (IV) or terbutaline (SC) Previous Maintenance Tocolytics: Oral tocolytics (only received by some patients) Inclusion Criteria: 20 to 35 weeks gestation; established diagnosis of preterm labor; intact membranes; cervical dilation ≤ 4 cm Exclusion Criteria: Contraindication to terbutaline therapy (abnormal fetal heart rate pattern, complete abruption placentae, chorioamnionitis, and progressive preeclampsia). | Uterine contractions > four per hour and progressive cervical change. | I: SQ terbutaline (51): NR | Medium There is missing information, which makes it difficult to assess some quality items. However, there was no high loss to followup and subjects were representative of source population. Adequacy of sample size is unclear (n=51), although it is larger than the previous case series of nine subjects.
First Author (year): Lam (1988)^22^ Design: Case Series Setting: NR Funding Source: NR | n = 9 Mean Maternal Age ± SD (years): NR Mean Gestational Age ± SD (weeks): 29.6 ± 3.7 (T) Gestation: not specified Primary Tocolytic Treatment: Magnesium Sulfate (IV) Previous Maintenance Tocolytics: Oral Terbutaline Inclusion Criteria: had RPTL during oral terbutaline treatment; intact membranes; cervical dilation < 4 cm; absence of fetal distress or anomalies; absence of maternal disease with which magnesium sulfate or beta-mimetic tocolysis might interfere Exclusion Criteria: NR | Regular uterine contractions > four per hour leading to progressive cervical change. | I: SQ terbutaline (9): NR | Medium There is a lot of missing information, which makes it difficult to assess potential for selection bias (e.g., were the nine subjects in the study the entire sample, or were these the number left over after losses to followup?). Also, harm outcomes have not been defined. However, the study does not have any obvious major flaws, which would invalidate the results.

SC = subcutaneous; IV = intravenous; NR = not reported; PTL = preterm labor; SD = standard deviation; RPTL = recurrent preterm labor; RCT = randomized controlled trial; SQ = subcutaneous

* Either at preterm labor (indicated by P) or at start of subcutaneous terbutaline therapy (indicated by T). If study population stated RPTL as an inclusion criterion, then this is the gestational age at the episode of RPTL.

† Received by entire study population, unless specified otherwise.

‡ Data from a third treatment arm, which consisted of a control group without preterm labor, has not been presented.

Table F2 Full-text question posed for criteria listed in risk of bias charts

Risk of Bias Chart | Full Question
Baseline characteristics/ prognostic factors | Are the treatment and comparison groups similar in terms of baseline characteristics and prognostic factors?
Primary tocolytic agent(s) | Did participants in the treatment and comparison groups receive the same (or a similar distribution of) primary tocolytic to control their acute episode of preterm labor?
Level of care | Was there a differential level of care (e.g., home uterine contraction monitoring, education, nurse visits, individualized dosing schedules, other co-interventions) between the treatment and comparison groups?
Population used to sample comparison and treatment groups | If this is an observational study or a nonrandomized trial, is the sample population from which the comparison group(s) was drawn the same as the sample population from which the treatment group was drawn?
Loss to followup | Was there either: (i) a differential loss to followup between the compared groups; or (ii) an overall high loss to followup?
Compliance with study protocol | Was compliance with the study protocol (i.e., treatment or comparator intervention) adequate in all study groups?
Methods to control for confounders | If this is an observational study or a nonrandomized trial, were appropriate methods undertaken to control for important confounders (e.g., matching)?
Representativeness of subjects to source | Were the subjects who were included in the study representative of the source population? For instance, subjects would be representative if the entire source population was recruited for the study, if a sample of consecutive patients was recruited, or if a random sample was obtained.
Blinding of patients to treatment allocation | If this is an experimental study, were patients blinded to treatment allocation?
Blinding of health care providers to treatment allocation | If this is an experimental study, were healthcare providers blinded to treatment allocation?
Blinding of outcome assessors to treatment allocation | If this is an experimental study, was the outcome assessor blinded to treatment allocation?
Blinding of health care providers to maternal contractions | If this is an experimental study, were healthcare providers blinded to the frequency and intensity of maternal contractions?
Generation of allocation sequence | If this is a randomized controlled trial, was the allocation sequence adequately generated?
Concealment of allocation sequence | If this is a randomized controlled trial, was the process of concealing the random allocation sequence adequate?
Prediction of future intervention assignments by study personnel | If this is a randomized controlled trial, at the time of study enrollment is there any indication that study personnel were able to predict future intervention assignments?
Intention-to-treat analysis | Was an intention-to-treat analysis conducted?
Sample size | Was the sample size adequate to determine a difference in outcomes between comparison groups or between pre and post intervention?
Selective outcome reporting | Is there any indication of selective outcome reporting?
Reliability in outcome assessment (if multiple outcome assessors used) | If multiple outcome assessors were used, is it likely there was high reliability in outcome assessment between all assessors (e.g., inter-rater reliability testing was conducted and adequate)?
Consistency in outcome definition | If this is a retrospective study that used multiple data sources, is it likely there was consistency in outcome definition across those data sources?
Definition of primary outcome(s) | Were the primary outcomes in the study defined by either prespecified or standardized clinical definitions?
Prespecification of harm outcomes | For studies assessing maternal or neonatal harms: If the harm outcomes assessed in the study are not generally known to have standard definitions, then were these harms predefined using standardized or precise definitions?
Reporting of harm outcomes as active | If this is a study assessing maternal or neonatal harms, was the mode of harms collection specified as active (versus passive)?
Reporting of training/background of personnel collecting harms data | If this is a study assessing maternal or neonatal harms, did the report specify who collected harms data, including their training and background?

Table F3 Detailed risk of bias assessments for individual studies

Study Design: Author (year) | Risk of Bias Criteria Rated Negatively | Risk of Bias Criteria Rated Positively | Risk of Bias Criteria Rated as Unclear | Final Rating by Outcome (rating applies to all outcomes unless indicated otherwise)
RCT: Guinn (1998)^9^ | | Groups similar in primary tocolytic therapy. Patients blinded to treatment allocation. Health care providers blinded to treatment allocation/Outcome assessor blinded to treatment allocation (assumed to be same as health care providers). Intention-to-treat analysis conducted. No differential or high loss to followup. Sample size adequate. No differential level of care among groups. No indication of selective outcome reporting. Allocation sequence was generated adequately. Allocation sequence concealed adequately. No indication that study personnel could predict future intervention assignments. Measured harms with standardized definition (maternal discontinuation of therapy). Mode of harms collection not explicitly specified as active. However, not relevant for harm of discontinuation of therapy. Report does not explicitly specify who collected harms data. However, not relevant for harm of discontinuation of therapy. Primary outcome (prolongation of pregnancy) has been defined. | If groups were similar in baseline characteristics and prognostic factors. If health care providers were blinded to maternal contractions. If there was reliability among multiple outcome assessors (unclear if there were multiple outcome assessors). If compliance with study protocol was adequate. Representativeness of subjects to source population. | Outcomes:; 1. Maternal discontinuation of therapy; 2. NICU admission; 3. Intraventricular hemorrhage; 4. Prolongation of pregnancy; 5. Gestational age at delivery; 6. Birth weight; LOW: The comparability of groups cannot be assessed for certain because information on all relevant factors has not been presented (e.g., prognostic factors, like cervical length and fetal fibronectin). However, randomization was carried out properly and patients/health care providers were blinded to treatment allocation, which will limit selection and detection biases.
RCT: Wenstrom (1997)^10^ Saline pump arm | Patients were not adequately blinded (the intention was to blind, but 60% in terbutaline pump group and 67% in saline pump group had to be unblinded). Healthcare providers were not adequately blinded (the intention was to blind, but 60% in terbutaline pump group and 67% in saline pump group had to be unblinded)/Same consideration applies to outcome assessors, since they are assumed to be the same as healthcare providers. Sample size too small. Harms outcomes do not have standard clinical definitions and were not predefined (local skin irritation, local pain, neonatal hypoglycemia). Mode of harms collection not specified as active. Report does not specify who collected harms, including training and background. Subjects were not representative of source population because >90% of eligible subjects declined to participate. | Intention-to-treat analysis conducted. No differential or high loss to followup. Allocation sequence generated adequately. Allocation sequence concealed adequately. No indication that study personnel could predict future intervention assignments. | If groups were similar in baseline characteristics and prognostic factors. If groups were similar in primary tocolytic therapy. If health care providers were blinded to maternal contractions. If there was differential level of care among groups. If there was selective outcome reporting. If there was reliability among multiple outcome assessors (unclear if there were multiple assessors). If compliance with study protocol was adequate. | Outcomes:; 1. Gestational age at delivery; 2. Birth weight; 3. Prolongation of pregnancy; 4. Local skin irritation; 5. Local pain; 6. Neonatal hypoglycemia; 7. Sepsis; 8. Retinopathy of prematurity; 9. NICU; 10. Perinatal deaths; HIGH: The sample likely represents a very select group, since >90% of eligible subjects declined to participate. The study is likely to be underpowered. There is evidence that randomization was carried out properly, but blinding was not that effective. Missing information makes it difficult to judge comparability of groups in baseline characteristics and prognostic factors, primary tocolytic therapy, and level of care.
RCT: Wenstrom (1997)^10^ Oral terbutaline arm | Patients were not blinded to treatment allocation. Health care providers were not blinded to treatment allocation/Same applies to outcome assessors since they are assumed to be the same as healthcare providers. Sample size too small. Harm outcomes do not have standard clinical definitions and were not predefined (local skin irritation, local pain, neonatal hypoglycemia). Mode of harms collection not specified as active. Report does not specify who collected harms, including training and background. Subjects were not representative of source population because >90% of eligible subjects declined to participate. | Intention-to-treat analysis conducted. No differential or high loss to followup. Allocation sequence generated adequately. Allocation sequence concealed adequately. No indication that study personnel could predict future intervention assignments. | If groups were similar in baseline characteristics and prognostic factors. If groups were similar in primary tocolytic therapy. If healthcare providers were blinded to maternal contractions. If there was differential level of care among groups. If there was selective outcome reporting. If there was reliability among multiple outcome assessors (unclear if there were multiple assessors). If compliance with study protocol was adequate. | Outcomes:; 1. Gestational age at delivery; 2. Birth weight; 3. Prolongation of pregnancy; 4. Local skin irritation; 5. Local pain; 6. Neonatal hypoglycemia; 7. Sepsis; 8. Retinopathy of prematurity; 9. NICU; 10. Perinatal deaths; HIGH: The sample likely represents a very select group, since >90% of eligible subjects declined to participate. The study is likely to be underpowered. There is evidence that randomization was carried out properly, but patient and healthcare providers were not blinded to treatment allocation. Missing information makes it difficult to judge comparability of groups in baseline characteristics and prognostic factors, primary tocolytic therapy, and level of care.
Nonrandomized Trial: Lindenbaum (1992)^11^ | Patients were not blinded to treatment allocation. Health care providers not blinded to treatment allocation/Same applies to outcome assessors, since they are assumed to be the same as health care providers. Health care providers not blinded to maternal contractions. Comparison group not drawn from same population as treatment group. Appropriate methods not taken to control for confounders. | No differential or high loss to followup. No indication of selective outcome reporting. Harm outcome (maternal hyperglycemia) was pre-defined. Mode of harms collection was specified as active. Report does not explicitly specify who collected harms data. However, GTT results will likely be obtained by trained laboratory personnel and interpreted by qualified healthcare professionals. Subjects were representative of source population. Primary outcome (maternal hyperglycemia) has been defined. | If groups were similar in baseline characteristics and prognostic factors. If groups were similar in primary tocolytic treatment. If an intention-to-treat analysis was conducted. If sample size was adequate. If there was differential level of care among groups. If there was reliability among multiple outcome assessors (unclear if there were multiple assessors). If compliance with study protocol was adequate. | Outcomes:; 1. Gestational age at delivery; 2. Birth weight; 3. Maternal hyperglycemia; HIGH (birthweight and gestational age at delivery): Primary flaw in this study is the difference in groups with respect to severity/prognosis (i.e., groups were divided based on length of primary tocolytic treatment). Also, comparability of groups cannot be assessed due to missing information. MEDIUM (maternal hyperglycemia): The potential difference in severity/prognosis among treatment and comparison groups should not impact the outcome of maternal hyperglycemia. However, issues pertaining to missing information still remain.
Prospective Cohort: Morrison (2003)^12^ | Groups differ in baseline characteristics and prognostic factors (in particular, differ in risk factors for preterm birth). Groups differ in primary tocolytic. Differential level of care received by groups (only terbutaline group received home uterine contraction monitoring. Indication of selective outcome reporting (amount terbutaline infused and neonatal morbidity not reported). Methods to control for confounders insufficient (matched for several factors, but there are still differences in the risk factors for preterm birth). Mode of harms collection not specified as active. | No differential or high loss to followup. Measured harms with standard definitions (maternal arrhythmia and maternal discontinuation of therapy). Report does not explicitly specify who collected harms data. However, it can be assumed that arrhythmia would be detected by qualified healthcare professionals. Subjects were representative of source population. | If an intention-to-treat analysis was conducted. If sample size adequate. If there was reliability among multiple outcome assessors (unclear if there were multiple outcome assessors). If compliance with study protocol was adequate. If comparison group was drawn from same population as treatment group. | Outcomes:; 1. Maternal arrhythmia; 2. Maternal discontinuation of therapy; 3. Gestational age at delivery; 4. Prolongation of pregnancy; 5. PPI; 6. Birth weight; 7. Intraventricular hemorrhage; 8. Necrotizing enterocolitis; 9. NICU admission; HIGH: Primary flaw with this study is that there is evidence that groups were not comparable (with respect to risk factors for preterm birth, primary tocolytic therapy, level of care).
Prospective Cohort: Morrison (1992)^13^ | Groups were not similar in baseline characteristics and prognostic factors (subcutaneous terbutaline group had RPTL but other group did not). Comparison group not drawn from the same population as treatment group. Appropriate methods not taken to control for confounders. | No indication of selective outcome reporting. Primary outcome has been defined (interval from discontinuance of tocolytic to spontaneous labor). | If groups were similar in primary tocolytic treatment. If an intention-to-treat analysis was conducted. If there was differential or high loss to followup. If sample size was adequate. If there was differential level of care among groups. If there was reliability among multiple outcome assessors (unclear if there were multiple assessors). If compliance with study protocol was adequate. If subjects were representative of source population. | Outcomes:; 1. Gestational age at delivery; HIGH: Major flaw is that the subcutaneous pump group had RPTL and comparison group did not. Therefore, the intervention group may have had a more serious condition. Also, there is missing information, which makes it difficult to assess other potential limitations.
Retrospective Cohort: Flick (2010)^14^ | Groups were not similar in baseline characteristics and prognostic factors (in particular, differed in smoking status). Appropriate methods not undertaken to control for confounders. | No differential or high loss to followup. No differential level of care. No indication of selective outcome reporting. Comparison group drawn from the same population as treatment group. Subjects were representative of source population. Primary outcome (prolongation of pregnancy) has been defined. | If groups were similar in primary tocolytic therapy. If an intention-to-treat analysis was conducted. If sample size was adequate. If there was reliability among multiple outcome assessors (data from Matria database, so likely there were multiple outcome assessors, but cannot determine reliability among them). If compliance with study protocol was adequate. | Outcomes:; 1. Prolongation of pregnancy; 2. Gestational age at delivery; 3. Birth weight; 4. NICU admission; HIGH: Primary flaw is that groups were not similar in baseline characteristics and prognostic factors (i.e. differed in smoking status). Also, missing information makes it difficult to assess similarity of groups with respect to other factors.
Retrospective Cohort:de la Torre (2008)^15^ | No methods to control for confounders. | No differential or high loss to followup. No differential level of care between groups. No indication of selective outcome reporting. Comparison and treatment groups drawn from same sample population. Subjects were representative of source population. Primary outcome (prolongation of pregnancy) was defined. | If groups were similar in baseline characteristics and prognostic factors. If groups were similar in primary tocolytic therapy. If intention-to-treat analysis conducted. If sample size adequate. If there was reliability among multiple outcome assessors (likely that there were multiple outcome assessors, since women were from the Matria database. But reliability among assessors cannot be assessed). If compliance with study protocol was adequate. | Outcomes:; 1. Prolongation of pregnancy; 2. Gestational age at delivery; 3. Birth weight; 4. NICU admission; MEDIUM: There is a lot of missing information, which makes it difficult to assess comparability of groups (in terms of baseline characteristics and prognostic factors, primary tocolytic therapy, and compliance). But difficult to say that there is any limitation that would invalidate the results for sure.
Retrospective Cohort: Fleming (2004)^16^ | Primary outcome of gestational age < 35 weeks has not been adequately specified (i.e., method for determining gestational age not described). | No differential level of care. No indication of selective outcome reporting. Comparison group drawn from same population as treatment group. | If groups were similar in baseline characteristics and prognostic factors. If groups were similar in primary tocolytic therapy. If intention-to-treat analysis conducted. If there was differential or high loss to followup. If sample size was adequate. If there was reliability in outcome assessors (likely that there were multiple outcome assessors, since the Matria database was used. But reliability among assessors cannot be determined). If compliance with study protocol was adequate. If appropriate methods were used to control for important confounders. If subjects were representative of source population. | Outcomes:; 1. Pregnancy prolongation; 2. Gestational age at delivery; 3. Stillbirths/neonatal deaths; 4. NICU admission; 5. Birth weight; MEDIUM: There is considerable missing information, which makes it difficult to assess the comparability of groups. There is some indication that there are baseline differences (i.e., in age and marital status) and data on many other important factors have not been reported (e.g., cervical length, race, SES). However, there are no major flaws that can be singled out as invalidating the results.
Retrospective Cohort: Lam (2003)^17^ | Groups differ in baseline characteristics and prognostic factors (in particular: smoking status and previous preterm delivery). Intention-to-treat analysis not done (losses to followup excluded). Methods were not sufficient to control for confounders (only matched by gestational age at delivery). | No differential level of care between groups. Comparison group drawn from the same sample population as treatment group. Measured harms with standardized definitions (maternal pulmonary edema and maternal death). Mode of harms collection not explicitly specified as active. However, this is not very relevant for outcomes of pulmonary edema and maternal death. Report does not explicitly specify who collected harms data. However, it is reasonable to assume that pulmonary edema would be assessed by qualified healthcare professionals. | If groups were similar in primary tocolytic therapy. If there was differential or high loss to followup (losses to followup were excluded). If sample size was adequate. If there was selective outcome reporting. If there was reliability in outcome assessors (data was from Matria database, so likely that there were multiple outcome assessors. But reliability among assessors cannot be determined). If compliance with study protocol was adequate. If subjects were representative of source population. | Outcomes:; 1. Pregnancy prolongation; 2. Gestational age at delivery; 3. Birth weight; 4. NICU admission; 5. Stillbirth; 6. Ventilator required; 7. Maternal pulmonary edema; 8. Maternal deaths; HIGH: Primary flaw is that groups were not similar at baseline (differed in smoking status and previous PTD). Also, missing data makes it difficult to assess several other potential limitations.
Retrospective Cohort: Lam (2001)^18^ | | No high or differential loss to followup. No differential level of care among groups. Comparison group drawn from same population as treatment group. Measured harms with standard definitions (maternal pulmonary edema and maternal deaths). Mode of harms collection not explicitly specified as active. However, this is not very relevant for harms of maternal pulmonary edema and maternal death. Report does not explicitly specify who collected harms data. However, it can be assumed that pulmonary edema and death would be assessed by qualified personnel. Subjects were representative of source population. | If groups were similar in baseline characteristics and prognostic factors. If groups were similar in primary tocolytic therapy. If an intention-to-treat analysis was conducted. If sample size was adequate. If there was selective outcome reporting. If there was reliability among multiple outcome assessors (data from Matria database, so likely there were multiple outcome assessors, but reliability among assessors cannot be determined). If compliance with study protocol was adequate. If appropriate methods used to control for confounders (matched by gestational age at hospitalization for recurrent preterm labor). | Outcomes:; 1. Prolongation of pregnancy; 2. Gestational age at delivery; 3. Birth weight; 4. NICU admission; 5. Stillbirth/neonatal deaths; 6. Maternal pulmonary edema; 7. Maternal deaths; MEDIUM: There is a large amount of missing information, which makes it difficult to assess the comparability of groups and other potential limitations. But there are no major flaws that can be identified that would invalidate the results.
Retrospective Cohort: Allbert (1994)^19^ | Differential level of care among groups (it appears that only the subcutaneous terbutaline group received home nursing care). | No indication of selective outcome reporting. Consistency in outcome definition among multiple data sources (Not clear if multiple data sources were used. However, use of multiple data sources should not make much of a difference because all outcomes have been defined or are self-explanatory). Primary outcome defined (gestational age ≥ 37 weeks and method for determining gestational age specified). | If groups were similar in baseline characteristics and prognostic factors. If groups were similar in primary tocolytic therapy. If an intention-to-treat analysis was conducted. If there was high or differential loss to followup. If sample size was adequate. Reliability among multiple outcome assessors (unclear of there were multiple assessors). If compliance with study protocol was adequate. If comparison group came from same sample population as treatment group. If appropriate methods were undertaken to control for confounders (matched for age, race, parity, gestational age and cervical dilation at the diagnosis of recurrent labor). If subjects were representative of source population. | Outcomes:; 1. Gestational age at delivery; 2. PPI; 3. Birth weight; MEDIUM: There is a lot of missing information, which makes it difficult to assess comparability among groups and whether groups were derived from the same population. There is a possibility that groups received a different level of care, since only the subcutaneous terbutaline group has been specified as receiving home nursing care. However, it is unclear if this factor alone would be sufficient to impact the results to a large extent.
Retrospective Cohort: Regenstein (1993)^20^ | Groups are not similar in baseline characteristics and prognostic factors. No methods to control for confounders. | No bias due to study funding. No indication of selective outcome reporting. Harm outcome (maternal hyperglycemia) was predefined using precise definition based on 3-hour GTT. Harms data collection was specified as active versus passive. Report does not explicitly specify who collected harms data, including their training and background. However, GTT results will likely be obtained by trained laboratory personnel and interpreted by qualified health care professionals. Primary outcome (glucose intolerance i.e. maternal hyperglycemia) is defined based on 1-hour and 3-hour GTT. | If groups were similar in primary tocolytic therapy. If intention-to-treat analysis conducted. If there was differential or high loss to followup. If sample size adequate. If there was differential level of care between groups. If there was reliability among multiple outcome assessors (unclear if there were multiple outcome assessors). If compliance with study protocol was adequate. If comparison group was drawn from the same population as treatment group. If subjects were representative of source population. | Outcomes:; 1. Maternal hyperglycemia (gestational diabetes); 2. Gestational age at delivery; 3. Birth weight; HIGH (Maternal hyperglycemia - harm outcome): Although this harm outcome was defined and collected actively, the primary flaw with this study is that groups were not similar in baseline characteristics (i.e., in race and family history of gestational diabetes). Also, since no methods were used to control for confounders, there is a high likelihood that groups may differ in other baseline characteristics and prognostic factors, which have not been reported. There is also a lot of missing information which makes it difficult to assess the comparability of groups (e.g. primary tocolytic, loss to followup, differential level of care, compliance). HIGH (all other outcomes): same reasons as above.
Case series: Adkins (1993)^21^ | Bias due to study funding (from PharmaThera Inc). Harms were not predefined (pump malfunction and dislodgment). Mode of harms collection not specified as active. Report does not specify who collected harms data, including background and training. | No high loss to followup. Subjects were representative of source population. | If sample size was adequate. If there was selective outcome reporting. If there was reliability among multiple outcome assessors (unclear if there were multiple assessors). If compliance with study protocol was adequate. | Outcomes:; 1. Pump malfunction; 2. Dislodgment; MEDIUM: There is missing information, which makes it difficult to assess some quality items. However, there was no high loss to followup and subjects were representative of source population. Adequacy of sample size is unclear (n=51), although it is larger than the previous case series of nine subjects.
Case series: Lam (1988)^22^ | Harm outcomes of mechanical failures/complications and infusion site infections have not been defined. Harms data collection not specified as active. Report does not specify who collected harms data, including their training and background. | | If there was high loss to followup. If sample size was adequate. If there was selective outcome reporting. If there was reliability among multiple outcome assessors (unclear if there were multiple assessors). If compliance with study protocol was adequate. If subjects were representative of source population. | Outcomes:; 1. Mechanical failures and complications; 2. Infusion site infection; MEDIUM: There is a lot of missing information, which makes it difficult to assess potential for selection bias (e.g., were the nine subjects in the study the entire sample, or were these the number left over after losses to followup?). Also, harm outcomes have not been defined. However, the study does not have any obvious major flaws, which would invalidate the results.

GTT = glucose tolerance test; NICU = neonatal intensive care unit; PPI = pregnancy prolongation index; PTD = preterm delivery; RCT = randomized controlled trial; SES = socioeconomic status

Table F4 Studies that reported neonatal health outcomes (Key Question 1)

Outcome | First Author (Year) | Study Design (n=Sample Size) | Mean Maternal Age (Years) | Mean GA (Weeks)^*^ | Comparator(s) | Results—SQ Terbutaline Pump: % (n/N) | Results—Comparison: % (n/N) | Results—OR (95% CI)
BPD | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Death, neonatal | Fleming^†^, (2004)^16^ | Retrospective Cohort (n=284) | NR | 30.4 ± 2.6 (P) | Oral nifedipine | 0% (0/142) | 0% (0/142) | 1.00 (0.02, 50.75)
Death, neonatal | Lam,†,‡ (2001)^18^ | Retrospective Cohort (n=706) | 28.8 ± 5.5 | 31.3 ± 2.3 (P) | Oral tocolytics (92.3% received oral terbutaline) | 0.1% (1/706) | 1.6% (11/706) | 0.09 (0.01, 0.70)
Death, neonatal | Wenstrom^§^ (1997)^10^ | RCT (n=42) | 26.2 ± 5.3 | 30.4 ± 2.3 (T) | Placebo (C_1_) Oral terbutaline (C_2_) | 0% (0/19) | C_1_: 0% (0/15) C_2_: 0% (0/16) | 0.79 (0.01, 42.38) 0.85 (0.02, 45.00)
Death within initial hospitalization | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A
IVH (Grade III/IV) | Morrison^†^ (2003)^12^ | Prospective Cohort (n=60) | 25.6 ± 5.2 | 29.5 ± 2.3 (P) | No treatment | 0% (0/15) | 8.9% (4/45) | 0.30 (0.02, 5.85)
IVH (Grade III/IV) | Guinn (1998) ^9^ | RCT (n=52) | 21.6 ± 5.7 | 30.6 ± 2.8 (T) | Placebo | 0% (0/23)^**^ | 0% (0/28) | 1.21 (0.02, 63.48)
NEC | Morrison^†^ (2003)^12^ | Prospective Cohort (n=60) | 25.6 ± 5.2 | 29.5 ± 2.3 (P) | No treatment | 0% (0/15) | 2.2% (1/45) | 0.96 (0.04, 24.74)
PVL | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Retinopathy of prematurity | Wenstrom^§^ (1997)^10^ | RCT (n=42) | 26.2 ± 5.3 | 30.4 ± 2.3 (T) | Placebo (C_1_) Oral terbutaline (C_2_) | 5.3% (1/19) | C_1_: 0% (0/15) C_2_: 0% (0/16) | 2.51 (0.10, 66.20) 2.68 (0.10, 70.31)
Seizures | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Sepsis | Wenstrom^§^ (1997)^10^ | RCT (n=42) | 26.2 ± 5.3 | 30.4 ± 2.3 (T) | Placebo (C_1_) Oral terbutaline (C_2_) | 0% (0/19) | C_1_: 0% (0/15) C_2_: 6.2% (1/16) | 0.79 (0.01, 42.38) 0.26 (0.01, 6.97)
Stillbirth | Fleming^†^ (2004)^16^ | Retrospective Cohort (n=284) | NR | 30.4 ± 2.6 (P) | Oral nifedipine | 1.4% (2/142) | 0.7% (1/142) | 2.01 (0.18, 22.47)
Stillbirth | Lam,† (2003)^17^ | Retrospective Cohort (n=558) | 27.4 ± 5.9 | 31.6 ± 2.2 (P) | Oral tocolytics (95.3% received oral terbutaline) | 0.4% (1/279) | 0% (0/279) | 3.01 (0.12, 74.23)
Stillbirth | Lam,†,‡ (2001)^18^ | Retrospective Cohort (n=706) | 28.8 ± 5.5 | 31.3 ± 2.3 (P) | Oral tocolytics (92.3% received oral terbutaline) | 0.4% (3/706) | 0.6% (4/706) | 0.75 (0.17, 3.36)

BPD = bronchopulmonary dysplasia; CI = confidence interval; GA = gestational age; IVH = intraventricular hemorrhage; N/A = not applicable; NEC = necrotizing enterocolitis; NR = not reported; OR = odds ratio; PVL = periventricular leukomalacia; RCT = randomized controlled trial; SQ = subcutaneous

Note: Subjects were women with singleton gestation only, unless indicated otherwise.

* Either at preterm labor (indicated by P) or at start of subcutaneous terbutaline therapy (indicated by T). If study population stated RPTL as an inclusion criterion, then this is the gestational age at the episode of RPTL.

† Study population consisted exclusively of women with RPTL.

‡ Study population consisted exclusively of women with twin gestation. Denominator is number of infants.

§ Study population consisted of women with single and twin gestation. Denominator is number of infants.

** One infant born at 33 weeks' gestation was unavailable for followup.

Table F5 Studies that reported mean gestational age at delivery (Key Question 2)

Outcome | First Author (Year) | Study Design (n=Sample Size) | Mean Maternal Age (Years) | Mean GA (Weeks)^*^ | Comparator(s) | Results—SQ Terbutaline Pump: Mean ± SD | Results—Comparison: Mean ± SD | Results—Difference in Means (95% CI)
Mean GA at delivery Results are reported as mean GA at delivery in weeks | Flick^†^ (2010)^14^ | Retrospective cohort (n=1366) | 28.7 ± 6.1 | 30.6 ± 2.9 (P) | Oral nifedipine | 36.7 ± 1.9 | 36.0 ± 2.9 | 0.70 (0.42, 0.98)
Mean GA at delivery Results are reported as mean GA at delivery in weeks | de la Torre^†, **^ (2008) ^15^ | Retrospective cohort (n=656) | 30.3 ± 5.8 | 30.1 ± 2.9 (P) | Oral nifedipine | 34.8 ± 2.2 | 34.1 ± 2.5 | 0.70 (0.43, 0.97)
Mean GA at delivery Results are reported as mean GA at delivery in weeks | Fleming^†^ (2004)^16^ | Retrospective cohort (n=284) | NR | 30.4 ± 2.6 (P) | Oral nifedipine | 36.6 ± 2.1 | 35.7 ± 3.1 | 0.90 (0.28, 1.52)
Mean GA at delivery Results are reported as mean GA at delivery in weeks | Lam,† (2003)^17^ | Retrospective cohort (n=558) | 27.4 ± 5.9 | 31.6 ± 2.2 (P) | Oral tocolytics (95.3% received oral terbutaline) | 36.5 ± 2.1 | 35.7 ± 2.8 | 0.80 (0.39, 1.21)
Mean GA at delivery Results are reported as mean GA at delivery in weeks | Morrison^†^ (2003)^12^ | Prospective cohort (n=60) | 25.6 ± 5.2 | 29.5 ± 2.3 (P) | No treatment | 36.7 ± 1.7 | 33.3 ± 3.0 | 3.40 (1.80, 5.00)
Mean GA at delivery Results are reported as mean GA at delivery in weeks | Lam,†,** (2001)^18^ | Retrospective cohort (n=706) | 28.8 ± 5.5 | 31.3 ± 2.3 (P) | Oral tocolytics (92.3% received oral terbutaline) | 35.2 ± 2.0 | 34.5 ± 2.3 | 0.70 (0.48, 0.92)
Mean GA at delivery Results are reported as mean GA at delivery in weeks | Guinn (1998) ^9^ | RCT (n=52) | 21.6 ± 5.7 | 30.6 ± 2.8 (T) | Placebo | 34.4 ± 3.4 | 34.9 ± 4.1 | -0.50 (-2.57, 1.57)
Mean GA at delivery Results are reported as mean GA at delivery in weeks | Wenstrom^††^ (1997)^10^ | RCT (n=42) | 26.2 ± 5.3 | 30.4 ± 2.3 (T) | Placebo (C_1_) Oral terbutaline (C_2_) | 35.7 ± 3.0 | C_1_: 35.4 ± 3.0 C_2_: 34.3 ± 4.0 | 0.30 (-1.73, 2.33) 1.40 (-0.92, 3.72)
Mean GA at delivery Results are reported as mean GA at delivery in weeks | Regenstein^‡‡^ (1993)^20^ | Retrospective cohort (n=69) | 31.4 ± 5.9 | NR | Oral terbutaline^§^ | 35.2 ± 3.3 | 36.6 ± 2.7 | -1.40 (-2.82, 0.02)
Mean GA at delivery Results are reported as mean GA at delivery in weeks | Lindenbaum (1992) ^11^ | Nonrandomized comparative trial (n=91) | 32.4 ± 2.7 | 29.1 ± 1.7 (T) | Oral terbutaline^§^ | 36.6 ± 1.2 | 37.9 ± 1.3 | -1.30 (-1.83, -0.77)^‡‡‡^
Mean GA at delivery Results are reported as mean GA at delivery in weeks | Morrison^***,†††^ (1992)^13^ | Prospective cohort (n=69) | 28.6 ± 4.7 | NR | Oral tocolytics | 37.5 ± 1.2 | 37.1 ± 0.96 | 0.40 (-0.11, 0.91)

CI = confidence interval; GA = gestational age; NR = not reported; RCT = randomized controlled trial; SD = standard deviation; SQ = subcutaneous

Note: Subjects were women with singleton gestation only, unless indicated otherwise.

* Either at preterm labor (indicated by P) or at start of subcutaneous terbutaline therapy (indicated by T). If study population stated RPTL as an inclusion criterion, then this is the gestational age at the episode of RPTL.

† Study population consisted exclusively of women with RPTL.

§ A third comparison arm (control group) was not extracted because this group did not have preterm labor.

** Study population consisted exclusively of women with twin gestation.

†† Study population consisted of women with single and twin gestation.

‡‡ Gestation not specified, although study population likely consisted of women with single and multiple gestation.

*** Gestational age at delivery was calculated by adding the variables gestational age at tocolytic cessation and interval to delivery. The associated standard deviations were calculated based on the reported standard deviations for interval to delivery (standard deviation of gestational age at tocolytic cessation was assumed to be 0 for both groups).

††† Gestation not specified, although study population likely included a mixture of women with single and multiple gestation.

‡‡‡ There were discrepancies in the information presented in the text and table of this paper. Mean gestational age at delivery for SQ terbutaline pump was reported as 36.6 weeks in table (as reported above) and 37.2 weeks in text.

Table F6 Studies that reported incidence of delivery at various gestational ages (Key Question 2)

Outcome | First Author (Year) | Study Design (n=Sample Size) | Mean Maternal Age (Years) | Mean GA (Weeks)^*^ | Comparator(s) | Results—SQ Terbutaline Pump: % (n/N) | Results—Comparison: % (n/N) | Results—OR (95% CI)
Incidence of delivery < 28 weeks | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Incidence of delivery < 32 weeks | Flick^†^ (2010)^14^ | Retrospective cohort (n=1366) | 28.7 ± 6.1 | 30.6 ± 2.9 (P) | Oral nifedipine | 2.6% (14/536) | 8.4% (70/830) | 0.29 (0.16, 0.52)
Incidence of delivery < 32 weeks | de la Torre^†,‡^ (2008)^15^ | Retrospective cohort (n=656) | 30.3 ± 5.8 | 30.1 ± 2.9 (P) | Oral nifedipine | 9.2% (44/476) | 17.7% (148/836) | 0.47 (0.33, 0.68)
Incidence of delivery < 32 weeks | Fleming^†^ (2004)^16^ | Retrospective cohort (n=284) | NR | 30.4 ± 2.6 (P) | Oral nifedipine | 2.8% (4/142) | 12.7% (18/142) | 0.20 (0.07, 0.61)
Incidence of delivery < 32 weeks | Lam,† (2003)^17^ | Retrospective cohort (n=558) | 27.4 ± 5.9 | 31.6 ± 2.2 (P) | Oral tocolytics (95.3% received oral terbutaline) | 2.5% (7/279) | 10.8%(30/279) | 0.21 (0.09, 0.50)
Incidence of delivery < 32 weeks | Morrison^†^ (2003)^12^ | Prospective cohort (n=60) | 25.6 ± 5.2 | 29.5 ± 2.3 (P) | No treatment | 0% (0/15) | 46.7% (21/45) | 0.04 (0.00, 0.65)
Incidence of delivery < 32 weeks | Lam,†,‡ (2001)^18^ | Retrospective cohort (n=706) | 28.8 ± 5.5 | 31.3 ± 2.3 (P) | Oral tocolytics (92.3% received oral terbutaline) | 6.2% (44/706) | 11.3% (80/706) | 0.52 (0.35, 0.76)
Incidence of delivery < 34 weeks | Guinn (1998) ^9^ | RCT (n=52) | 21.6 ± 5.7 | 30.6 ± 2.8 (T) | Placebo | 41.7% (10/24) | 42.8% (12/28) | 0.95 (0.32, 2.87)
Incidence of delivery < 37 weeks | Flick^†^ (2010)^14^ | Retrospective cohort (n=1366) | 28.7 ± 6.1 | 30.6 ± 2.9 (P) | Oral nifedipine | 51.3% (275/536) | 59.3% (492/830) | 0.72 (0.58, 0.90)
Incidence of delivery < 37 weeks | Fleming^†^ (2004)^16^ | Retrospective cohort (n=284) | NR | 30.4 ± 2.6 (P) | Oral nifedipine | 52.1% (74/142) | 59.2% (84/142) | 0.75 (0.47, 1.20)
Incidence of delivery < 37 weeks | Lam,† (2003)^17^ | Retrospective cohort (n=558) | 27.4 ± 5.9 | 31.6 ± 2.2 (P) | Oral tocolytics (95.3% received oral terbutaline) | 52.7% (147/279) | 61.3% (171/279) | 0.70 (0.50, 0.98)
Incidence of delivery < 37 weeks | Morrison^†^ (2003)^12^ | Prospective cohort (n=60) | 25.6 ± 5.2 | 29.5 ± 2.3 (P) | No treatment | 46.7% (7/15) | 95.6% (43/45) | 0.04 (0.01, 0.23)
Incidence of delivery < 37 weeks | Guinn (1998) ^9^ | RCT (n=52) | 21.6 ± 5.7 | 30.6 ± 2.8 (T) | Placebo | 70.8% (17/24) | 60.7% (17/28) | 1.57 (0.49, 5.02)
Incidence of delivery < 37 weeks | Allbert^†,§^ (1994)^19^ | Retrospective cohort (n=64) | 27.5 ± 4.3 | 32.2 ± 2.7 (T) | Oral terbutaline | 34.4% (11/32) | 84.4% (27/32) | 0.10 (0.03, 0.32)

CI = confidence interval; GA = gestational age; N/A = not applicable; NR = not reported; OR = odds ratio; RCT = randomized controlled trial; SQ = subcutaneous

Note: Subjects were women with singleton gestation only, unless indicated otherwise.

* Either at preterm labor (indicated by P) or at start of subcutaneous terbutaline therapy (indicated by T). If study population stated RPTL as an inclusion criterion, then this is the gestational age at the episode of RPTL.

† Study population consisted exclusively of women with RPTL.

‡ Study population consisted exclusively of women with twin gestation. Denominator is number of infants.

§ Gestation not specified, although population most likely included women with single and multiple gestation. Denominator is number of women.

Table F7 Studies that reported prolongation of pregnancy (Key Question 2)

Outcome | First Author (Year) | Study Design (n=Sample Size) | Mean Maternal Age (Years) | Mean GA (weeks)^*^ | Comparator(s) | Results—SQ Terbutaline Pump: Mean ± SD or % (n/N) | Results—Comparison: Mean ± SD or % (n/N) | Results—Either Difference in Means (95% CI) or OR (95% CI)
Mean prolongation of pregnancy Results are reported as mean prolongation in days | Flick^†^ (2010)^14^ | Retrospective cohort (n=1366) | 28.7 ± 6.1 | 30.6 ± 2.9 (P) | Oral nifedipine | 44.0 ± 23.0 | 36.5 ± 24.0 | 7.50 (4.94, 10.06)
Mean prolongation of pregnancy Results are reported as mean prolongation in days | Flick^†^ (2010)^14^ | Retrospective cohort (n=1366) | 28.7 ± 6.1 | 30.6 ± 2.9 (P) | Oral nifedipine | Measured from hospital admission for RPTL | | 7.50 (4.94, 10.06)
Mean prolongation of pregnancy Results are reported as mean prolongation in days
Mean prolongation of pregnancy Results are reported as mean prolongation in days | de la Torre^†,‡^ (2008)^15^ | Retrospective cohort (n=656) | 30.3 ± 5.8 | 30.1 ± 2.9 (P) | Oral nifedipine | 34.7 ± 18.8 | 27.5 ± 19.9 | 7.20 (4.10, 10.30)
Mean prolongation of pregnancy Results are reported as mean prolongation in days | de la Torre^†,‡^ (2008)^15^ | Retrospective cohort (n=656) | 30.3 ± 5.8 | 30.1 ± 2.9 (P) | Oral nifedipine | Measured from episode of RPTL | | 7.20 (4.10, 10.30)
Mean prolongation of pregnancy Results are reported as mean prolongation in days
Mean prolongation of pregnancy Results are reported as mean prolongation in days | Fleming^†^ (2004)^16^ | Retrospective cohort (n=284) | NR | 30.4 ± 2.6 (P) | Oral nifedipine | 43.3 ± 21.6 | 37.1 ± 24.8 | 6.20 (0.79, 11.61)
Mean prolongation of pregnancy Results are reported as mean prolongation in days | Fleming^†^ (2004)^16^ | Retrospective cohort (n=284) | NR | 30.4 ± 2.6 (P) | Oral nifedipine | Measured from episode of RPTL | | 6.20 (0.79, 11.61)
Mean prolongation of pregnancy Results are reported as mean prolongation in days
Mean prolongation of pregnancy Results are reported as mean prolongation in days | Lam,† (2003)^17^ | Retrospective cohort (n=558) | 27.4 ± 5.9 | 31.6 ± 2.2 (P) | Oral tocolytics (95.3% received oral terbutaline) | 33.9 ± 19.0 | 28.4 ± 19.8 | 5.50 (2.28, 8.72)
Mean prolongation of pregnancy Results are reported as mean prolongation in days | Lam,† (2003)^17^ | Retrospective cohort (n=558) | 27.4 ± 5.9 | 31.6 ± 2.2 (P) | Oral tocolytics (95.3% received oral terbutaline) | Measurement interval not specified | | 5.50 (2.28, 8.72)
Mean prolongation of pregnancy Results are reported as mean prolongation in days
Mean prolongation of pregnancy Results are reported as mean prolongation in days | Morrison^†^ (2003)^12^ | Prospective cohort (n=60) | 25.6 ± 5.2 | 29.5 ± 2.3 (P) | No treatment | 49.8 ± 19.2 | 24.5 ± 12.8 | 25.30 (16.77, 33.83)
Mean prolongation of pregnancy Results are reported as mean prolongation in days | Morrison^†^ (2003)^12^ | Prospective cohort (n=60) | 25.6 ± 5.2 | 29.5 ± 2.3 (P) | No treatment | Measured from episode of RPTL | | 25.30 (16.77, 33.83)
Mean prolongation of pregnancy Results are reported as mean prolongation in days
Mean prolongation of pregnancy Results are reported as mean prolongation in days | Guinn (1998) ^9^ | RCT (n=52) | 21.6 ± 5.7 | 30.6 ± 2.8 (T) | Placebo | 28.8 ± 22.0 | 27.9 ± 22.9 | 0.90 (-11.36, 13.16)
Mean prolongation of pregnancy Results are reported as mean prolongation in days | Guinn (1998) ^9^ | RCT (n=52) | 21.6 ± 5.7 | 30.6 ± 2.8 (T) | Placebo | Measured from random assignment | | 0.90 (-11.36, 13.16)
Mean prolongation of pregnancy Results are reported as mean prolongation in days
Mean prolongation of pregnancy Results are reported as mean prolongation in days | Wenstrom^§^ (1997)^10^ | RCT (n=42) | 26.2 ± 5.3 | 30.4 ± 2.3 (T) | Placebo (C_1_) Oral terbutaline (C_2_) | 35.0 ± 28.7 | C_1_: 35.0 ± 17.5 C_2_: 29.4 ± 27.3 | 0.00 (-18.53, 18.53) 5.60 (-14.45, 25.65)
Mean prolongation of pregnancy Results are reported as mean prolongation in days | Wenstrom^§^ (1997)^10^ | RCT (n=42) | 26.2 ± 5.3 | 30.4 ± 2.3 (T) | Placebo (C_1_) Oral terbutaline (C_2_) | Measurement interval not specified | | 0.00 (-18.53, 18.53) 5.60 (-14.45, 25.65)
Pregnancy prolongation > 7 days | Flick^†^ (2010)^14^ | Retrospective cohort (n=1366) | 28.7 ± 6.1 | 30.6 ± 2.9 (P) | Oral nifedipine | 98.7% (529/536) | 90.6% (752/830) | 7.84 (3.59, 17.12)
Pregnancy prolongation > 7 days | Flick^†^ (2010)^14^ | Retrospective cohort (n=1366) | 28.7 ± 6.1 | 30.6 ± 2.9 (P) | Oral nifedipine | Measured from hospital admission for RPTL | | 7.84 (3.59, 17.12)
Pregnancy prolongation > 7 days
Pregnancy prolongation > 7 days | Fleming^†^ (2004)^16^ | Retrospective cohort (n=284) | NR | 30.4 ± 2.6 (P) | Oral nifedipine | 96.5% (137/142) | 91.5% (130/142) | 2.53 (0.87, 7.38)
Pregnancy prolongation > 7 days | Fleming^†^ (2004)^16^ | Retrospective cohort (n=284) | NR | 30.4 ± 2.6 (P) | Oral nifedipine | Measured from episode of RPTL | | 2.53 (0.87, 7.38)
Pregnancy prolongation > 14 days | Flick^†^ (2010)^14^ | Retrospective cohort (n=1366) | 28.7 ± 6.1 | 30.6 ± 2.9 (P) | Oral nifedipine | 93.8% (503/536) | 81.4% (676/830) | 3.47 (2.34, 5.15)
Pregnancy prolongation > 14 days | Flick^†^ (2010)^14^ | Retrospective cohort (n=1366) | 28.7 ± 6.1 | 30.6 ± 2.9 (P) | Oral nifedipine | Measured from hospital admission for RPTL | | 3.47 (2.34, 5.15)
Pregnancy prolongation > 14 days
Pregnancy prolongation > 14 days | de la Torre^†,‡^ (2008)^15^ | Retrospective cohort (n=656) | 30.3 ± 5.8 | 30.1 ± 2.9 (P) | Oral nifedipine | 84.4% (201/238) | 68.7% (287/418) | 2.48 (1.65, 3.73)
Pregnancy prolongation > 14 days | de la Torre^†,‡^ (2008)^15^ | Retrospective cohort (n=656) | 30.3 ± 5.8 | 30.1 ± 2.9 (P) | Oral nifedipine | Measured from episode of RPTL | | 2.48 (1.65, 3.73)
Pregnancy prolongation > 14 days
Pregnancy prolongation > 14 days | Fleming^†^ (2004)^16^ | Retrospective cohort (284) | NR | 30.4 ± 2.6 (P) | Oral nifedipine | 93.0% (132/142) | 82.4% (117/142) | 2.82 (1.30, 6.12)
Pregnancy prolongation > 14 days | Fleming^†^ (2004)^16^ | Retrospective cohort (284) | NR | 30.4 ± 2.6 (P) | Oral nifedipine | Measured from episode of RPTL | | 2.82 (1.30, 6.12)
Pregnancy prolongation > 14 days
Pregnancy prolongation > 14 days | Lam,† (2003)^17^ | Retrospective cohort (n=558) | 27.4 ± 5.9 | 31.6 ± 2.2 (P) | Oral tocolytics (95.3% received oral terbutaline) | 85.7% (239/279) | 71.3% (199/279) | 2.40 (1.57, 3.67)
Pregnancy prolongation > 14 days | Lam,† (2003)^17^ | Retrospective cohort (n=558) | 27.4 ± 5.9 | 31.6 ± 2.2 (P) | Oral tocolytics (95.3% received oral terbutaline) | Measurement interval not specified | | 2.40 (1.57, 3.67)
Pregnancy prolongation > 14 days
Pregnancy prolongation > 14 days | Lam,†,‡ (2001)^18^ | Retrospective cohort (n=706) | 28.8 ± 5.5 | 31.3 ± 2.3 (P) | Oral tocolytics (92.3% received oral terbutaline) | 73.6% (260/353) | 59.2% (209/353)^**^ | 1.93 (1.40, 2.65)
Pregnancy prolongation > 14 days | Lam,†,‡ (2001)^18^ | Retrospective cohort (n=706) | 28.8 ± 5.5 | 31.3 ± 2.3 (P) | Oral tocolytics (92.3% received oral terbutaline) | Measured from episode of RPTL | | 1.93 (1.40, 2.65)

CI = confidence interval; GA = gestational age; N/A = not applicable; NR = not reported; OR = odds ratio; RCT = randomized controlled trial; RPTL = recurrent preterm labor; SD = standard deviation; SQ = subcutaneous

Note: Subjects were women with singleton gestation only, unless indicated otherwise.

* Either at preterm labor (indicated by P) or at start of subcutaneous terbutaline therapy (indicated by T). If study population stated RPTL as an inclusion criterion, then this is the gestational age at the episode of RPTL.

† Study population consisted exclusively of women with RPTL.

‡ Study population consisted exclusively of women with twin gestation.

§ Study population consisted of women with single and twin gestation.

** Additional reported data: SQ terbutaline pump group gained an average of 4.5 gestational days (95% CI: 2.3–6.8) compared with oral tocolytic group.^18^

Table F8 Studies that reported birth weight (Key Question 2)

Outcome | First Author (Year) | Study Design (n=Sample Size) | Mean Maternal Age (Years) | Mean GA (Weeks)^*^ | Comparator(s) | Results—SQ Terbutaline Pump: Mean ± SD or % (n/N) | Results—Comparison: Mean ± SD or % (n/N) | Results—Either Difference in Means (95% CI) or OR (95% CI)
Mean birth weight Results are reported as mean birth weight in grams | de la Torre^†,‡^ (2008)^15^ | Retrospective cohort (n=656) | 30.3 ± 5.8 | 30.1 ± 2.9 (P) | Oral nifedipine | 2252 ± 501 | 2089 ± 564 | 163 (102, 224)
Mean birth weight Results are reported as mean birth weight in grams | Fleming^†^ (2004)^16^ | Retrospective cohort (n=284) | NR | 30.4 ± 2.6 (P) | Oral nifedipine | 2900 ± 568 | 2638 ± 784 | 262 (103, 421)
Mean birth weight Results are reported as mean birth weight in grams | Lam,† (2003)^17^ | Retrospective cohort (n=558) | 27.4 ± 5.9 | 31.6 ± 2.2 (P) | Oral tocolytics (95.3% received oral terbutaline) | 2941 ± 556 | 2676 ± 667 | 265 (163, 367)
Mean birth weight Results are reported as mean birth weight in grams | Morrison^†^ (2003)^12^ | Prospective cohort (n=60) | 25.6 ± 5.2 | 29.5 ± 2.3 (P) | No treatment | 2700 ± 464 | 1979 ± 670 | 721 (355, 1087)
Mean birth weight Results are reported as mean birth weight in grams | Lam,†,‡ (2001)^18^ | Retrospective cohort (n=706) | 28.8 ± 5.5 | 31.3 ± 2.3 (P) | Oral tocolytics (92.3% received oral terbutaline) | 2343 ± 493 | 2207 ± 523 | 136 (83, 189)
Mean birth weight Results are reported as mean birth weight in grams | Guinn (1998) ^9^ | RCT (n=52) | 21.6 ± 5.7 | 30.6 ± 2.8 (T) | Placebo | 2349 ± 770 | 2324 ± 768 | 25 (-394, 444)
Mean birth weight Results are reported as mean birth weight in grams | Wenstrom^§^ (1997)^10^ | RCT (n=42) | 26.2 ± 5.3 | 30.4 ± 2.3 (T) | Placebo (C_1_) Oral terbutaline (C_2_) | 2688 ± 599 | C_1_: 2457 ± 727 C_2_: 2204 ± 808 | 231 (-214, 676) 484 (17, 951)
Mean birth weight Results are reported as mean birth weight in grams | Allbert^†,**^ (1994)^19^ | Retrospective cohort (n=64) | 27.5 ± 4.3 | 32.2 ± 2.7 (T) | Oral terbutaline | 2853 ± 702 | 2682 ± 528 | 171 (-133, 475)
Mean birth weight Results are reported as mean birth weight in grams | Regenstein^††^ (1993)^20^ | Retrospective cohort (n=69) | 31.4 ± 5.9 | NR | Oral terbutaline^‡‡^ | 2558 ± 838 | 3262 ± 567 | -704 (-1037, -371)
Mean birth weight Results are reported as mean birth weight in grams | Lindenbaum (1992) ^11^ | Nonrandomized comparative trial (n=91) | 32.4 ± 2.7 | 29.1 ± 1.7 (T) | Oral terbutaline^‡‡^ | 3017 ± 303 | 3229 ± 584 | -212 (-417, -7)^§§^
Incidence of low birth weight (< 2,500 g) | Flick^†^ (2010)^14^ | Retrospective cohort (n=1366) | 28.7 ± 6.1 | 30.6 ± 2.9 (P) | Oral nifedipine | 20.3% (109/536) | 32.9% (273/830) | 0.52 (0.40, 0.67)
Incidence of low birth weight (< 2,500 g) | de la Torre^†,‡^ (2008)^15^ | Retrospective cohort (n=656) | 30.3 ± 5.8 | 30.1 ± 2.9 (P) | Oral nifedipine | 67.2% (320/476) | 78.3% (655/836) | 0.57 (0.44, 0.73)
Incidence of low birth weight (< 2,500 g) | Fleming^†^ (2004)^16^ | Retrospective cohort (n=284) | NR | 30.4 ± 2.6 (P) | Oral nifedipine | 23.2% (33/142) | 43.0% (61/142) | 0.40 (0.24, 0.67)
Incidence of low birth weight (< 2,500 g) | Lam,† (2003)^17^ | Retrospective cohort (n=558) | 27.4 ± 5.9 | 31.6 ± 2.2 (P) | Oral tocolytics (95.3% received oral terbutaline) | 20.8% (58/279) | 38.0% (106/279) | 0.43 (0.29, 0.62)
Incidence of low birth weight (< 2,500 g) | Morrison^†^ (2003)^12^ | Prospective cohort (n=60) | 25.6 ± 5.2 | 29.5 ± 2.3 (P) | No treatment | 20.0% (3/15) | 51.1% (23/45) | 0.24 (0.06, 0.96)
Incidence of low birth weight (< 2,500 g) | Lam,†,‡ (2001)^18^ | Retrospective cohort (n=706) | 28.8 ± 5.5 | 31.3 ± 2.3 (P) | Oral tocolytics (92.3% received oral terbutaline) | 61.5% (432/702) | 71.5% (494/691) | 0.64 (0.51, 0.80)
Incidence of very low birth weight (< 1,500 g) | de la Torre^†,‡^ (2008)^15^ | Retrospective cohort (n=656) | 30.3 ± 5.8 | 30.1 ± 2.9 (P) | Oral nifedipine | 6.5% (31/476) | 15.0% (125/836) | 0.40 (0.26, 0.60)
Incidence of very low birth weight (< 1,500 g) | Fleming^†^ (2004)^16^ | Retrospective cohort (n=284) | NR | 30.4 ± 2.6 (P) | Oral nifedipine | 2.1% (3/142) | 7.0% (10/142) | 0.28 (0.08, 1.06)
Incidence of very low birth weight (< 1,500 g) | Lam,† (2003)^17^ | Retrospective cohort (n=558) | 27.4 ± 5.9 | 31.6 ± 2.2 (P) | Oral tocolytics (95.3% received oral terbutaline) | 1.4% (4/279) | 6.1% (17/279) | 0.22 (0.07, 0.67)
Incidence of very low birth weight (< 1,500 g) | Lam,†,‡ (2001)^18^ | Retrospective cohort (706) | 28.8 ± 5.5 | 31.3 ± 2.3 (P) | Oral tocolytics (92.3% received oral terbutaline) | 4.1% (29/702) | 8.5% (59/691) | 0.46 (0.29, 0.73)
Ratio of birth weight/GA at delivery | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A

CI = confidence interval; GA = gestational age; NR = not reported; OR = odds ratio; RCT = randomized controlled trial; SD = standard deviation; SQ = subcutaneous

Note: Subjects were women with singleton gestation only, unless indicated otherwise.

* Either at preterm labor (indicated by P) or at start of subcutaneous terbutaline therapy (indicated by T). If study population stated RPTL as an inclusion criterion, then this is the gestational age at the episode of RPTL.

† Study population consisted exclusively of women with RPTL.

‡ Study population consisted exclusively of women with twin gestation. Denominator is number of infants.

§ Study population consisted of women with single and twin gestation.

** Gestation not specified, although population most likely included women with single and multiple gestation.

†† Gestation not specified, although study population likely consisted of women with single and multiple gestation. Reported mean birthweight is for singletons only.

‡‡ A second comparison group, consisting of women without preterm labor, was not extracted.

§§ There were discrepancies in the information presented in the text and table of this paper. The table reported the numbers as indicated above. However, the text reported groups with the reverse numbers (i.e. SQ terbutaline pump: 3229 ± 584 and oral terbutaline: 3017 ± 303).

Table F9 Studies that reported other outcomes (Key Question 2)

Outcome | First Author (Year) | Study Design (n=Sample Size) | Mean Maternal Age (Years) | Mean GA (Weeks)^*^ | Comparator(s) | Results—SQ Terbutaline Pump: Mean ± SD or % (n/N) | Results—Comparison: Mean ± SD or % (n/N) | Results—Either Difference in Means (95% CI) or OR (95% CI)
Mean PPI | Morrison^†^ (2003)^12^ | Prospective cohort (n=60) | 25.6 ± 5.2 | 29.5 ± 2.3 (P) | No treatment | 0.92 ± 0.19 | 0.51 ± 0.28 | 0.41 (0.26, 0.56)
Mean PPI
Mean PPI | Allbert^†,**^ (1994)^19^ | Retrospective cohort (64) | 27.5 ± 4.3 | 32.2 ± 2.7 (T) | Oral terbutaline | 0.86 ± 0.25 | 0.72 ± 0.25 | 0.14 (0.02, 0.26)
Need for assisted ventilation | Lam,† (2003)^17^ | Retrospective cohort (n=558) | 27.4 ± 5.9 | 31.6 ± 2.2 (P) | Oral tocolytics (95.3% received oral terbutaline) | 24.4% (68/279) | 26.2% (73/279) | 0.91 (0.62, 1.33)
Need for assisted ventilation | Lam,† (2003)^17^ | Retrospective cohort (n=558) | 27.4 ± 5.9 | 31.6 ± 2.2 (P) | Oral tocolytics (95.3% received oral terbutaline) | Only assessed for those with NICU admission | | 0.91 (0.62, 1.33)
Need for oxygen per nasal cannula | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A
NICU admission incidence | Flick^†^ (2010)^14^ | Retrospective cohort (n=1366) | 28.7 ± 6.1 | 30.6 ± 2.9 (P) | Oral nifedipine | 23.1% (124/536) | 34.0% (282/830) | 0.58 (0.46, 0.75)
NICU admission incidence
NICU admission incidence | de la Torre^†,‡^ (2008)^15^ | Retrospective cohort (n=656) | 30.3 ± 5.8 | 30.1 ± 2.9 (P) | Oral nifedipine | 44.7% (213/476) | 52.9% (442/836) | 0.72 (0.58, 0.91)
NICU admission incidence
NICU admission incidence | Fleming^†^ (2004)^16^ | Retrospective cohort (n=284) | NR | 30.4 ± 2.6 (P) | Oral nifedipine | 23.2% (33/142) | 43.7% (62/142) | 0.39 (0.23, 0.65)
NICU admission incidence
NICU admission incidence | Lam,† (2003)^17^ | Retrospective cohort (n=558) | 27.4 ± 5.9 | 31.6 ± 2.2 (P) | Oral tocolytics (95.3% received oral terbutaline) | 18.6% (52/279) | 26.2% (73/279) | 0.65 (0.43, 0.97)
NICU admission incidence | Lam,† (2003)^17^ | Retrospective cohort (n=558) | 27.4 ± 5.9 | 31.6 ± 2.2 (P) | Oral tocolytics (95.3% received oral terbutaline) | NICU (Level III) admission | | 0.65 (0.43, 0.97)
NICU admission incidence
NICU admission incidence | Morrison^†^ (2003)^12^ | Prospective cohort (n=60) | 25.6 ± 5.2 | 29.5 ± 2.3 (P) | No treatment | 33.3% (5/15) | 64.4% (29/45) | 0.28 (0.08, 0.95)
NICU admission incidence
NICU admission incidence | Lam,†,‡ (2001)^18^ | Retrospective cohort (n=706) | 28.8 ± 5.5 | 31.3 ± 2.3 (P) | Oral tocolytics (92.3% received oral terbutaline) | 38.5% (270/702) | 55.0% (380/691) | 0.51 (0.41, 0.63)
NICU admission incidence
NICU admission incidence | Guinn (1998) ^9^ | RCT (n=52) | 21.6 ± 5.7 | 30.6 ± 2.8 (T) | Placebo | 43.5% (10/23) | 46.4% (13/28) | 0.89 (0.29, 2.69)
NICU admission incidence | Guinn (1998) ^9^ | RCT (n=52) | 21.6 ± 5.7 | 30.6 ± 2.8 (T) | Placebo | Neonates remaining in NICU >24 hours | | 0.89 (0.29, 2.69)
NICU mean length of stay Results are reported as mean length of stay in days | Flick^†^ (2010)^14^ | Retrospective cohort (n=1366) | 28.7 ± 6.1 | 30.6 ± 2.9 (P) | Oral nifedipine | 2.8 ± 9.2 | 6.5 ± 17.2 | -3.70 (-5.29, -2.11)
NICU mean length of stay Results are reported as mean length of stay in days
NICU mean length of stay Results are reported as mean length of stay in days | Lam,† (2003)^17^ | Retrospective cohort (n=558) | 27.4 ± 5.9 | 31.6 ± 2.2 (P) | Oral tocolytics(95.3% received oral terbutaline) | 14.1 ± 17.7 | 21.0 ± 22.5 | -6.90 (-10.26, -3.54)
NICU mean length of stay Results are reported as mean length of stay in days | Lam,† (2003)^17^ | Retrospective cohort (n=558) | 27.4 ± 5.9 | 31.6 ± 2.2 (P) | Oral tocolytics(95.3% received oral terbutaline) | NICU (Level III) admission | | -6.90 (-10.26, -3.54)
NICU mean length of stay Results are reported as mean length of stay in days
NICU mean length of stay Results are reported as mean length of stay in days | Morrison^†^ (2003)^12^ | Prospective cohort (n=60) | 25.6 ± 5.2 | 29.5 ± 2.3 (P) | No treatment | 1.9 ± 4.9 | 19.8 ± 29.3 | -17.90 (-32.88, -2.92)
NICU mean length of stay Results are reported as mean length of stay in days
NICU mean length of stay Results are reported as mean length of stay in days | Lam,†,‡ (2001)^18^ | Retrospective cohort (n=706) | 28.8 ± 5.5 | 31.3 ± 2.3 (P) | Oral tocolytics (92.3% received oral terbutaline) | 17.3 ± 16.1 | 20.8 ± 17.4 | -3.50 (-5.26, -1.74)
NICU mean length of stay Results are reported as mean length of stay in days
NICU mean length of stay Results are reported as mean length of stay in days | Wenstrom^§^ (1997)^10^ | RCT (n=42) | 26.2 ± 5.3 | 30.4 ± 2.3 (T) | Placebo (C_1_) Oral terbutaline (C_2_) | 10.9 ± 19.4 | C_1_: 15.0 ± 18.8 C_2_: 15.4 ± 17.0 | -4.10 (-17.06, 8.86) -4.50 (-16.70, 7.70)

CI = confidence interval; GA = gestational age; N/A = not applicable; NICU = neonatal intensive care unit; NR = not reported; OR = odds ratio; PPI = pregnancy prolongation index; RCT = randomized controlled trial; SD = standard deviation; SQ = subcutaneous

Note: Subjects were women with singleton gestation only, unless indicated otherwise.

* Either at preterm labor (indicated by P) or at start of subcutaneous terbutaline therapy (indicated by T). If study population stated RPTL as an inclusion criterion, then this is the gestational age at the episode of RPTL.

† Study population consisted exclusively of women with RPTL.

‡ Study population consisted exclusively of women with twin gestation. Denominator is number of infants.

§ Study population consisted of women with single and twin gestation.

** Gestation not specified, although population most likely included women with single and multiple gestation.

Table F10 Studies that reported maternal harms (Key Question 3)

Outcome | First Author (Year) | Study Design (n=Sample Size) | Mean Maternal Age (Years) | Mean GA (Weeks)^*^ | Comparator(s) | Results—SQ Terbutaline Pump: % (n/N) | Results—Comparison: % (n/N) | Results—OR (95% CI)
Arrhythmia | Morrison^†^ (2003)^12^ | Prospective cohort (n=60) | 25.6 ± 5.2 | 29.5 ± 2.3 (P) | No treatment | 20.0% (3/15) | 0% (0/45) | 25.48 (1.23, 526.64)
Arrhythmia | Morrison^†^ (2003)^12^ | Prospective cohort (n=60) | 25.6 ± 5.2 | 29.5 ± 2.3 (P) | No treatment | Defined as tachycardia, nervousness | | 25.48 (1.23, 526.64)
Heart failure | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Hyperglycemia Reported results indicate women with gestational diabetes, based on 3-hour GTT. | Regenstein^‡^ (1993)^20^ | Retrospective cohort (n=69) | 31.4 ± 5.9 | NR | Oral terbutaline^§^ | 20.0% (6/30) | 11.4% (4/35) | 1.94 (0.49, 7.65)
Hyperglycemia Reported results indicate women with gestational diabetes, based on 3-hour GTT.
Hyperglycemia Reported results indicate women with gestational diabetes, based on 3-hour GTT. | Lindenbaum (1992) ^11^ | Nonrandomized comparative trial (n=91) | 32.4 ± 2.7 | 29.1 ± 1.7 (T) | Oral terbutaline^§^ | 5.4% (2/37) | 11.1% (6/54) | 0.46 (0.09, 2.40)
Hypokalemia | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Mortality | Lam,† (2003)^17^ | Retrospective cohort (n=558) | 27.4 ± 5.9 | 31.6 ± 2.2 (P) | Oral tocolytics (95.3% received oral terbutaline) | 0% (0/279) | 0% (0/279) | 1 (0.02, 50.58)
Mortality
Mortality | Lam,†,** (2001)^18^ | Retrospective cohort (n=706) | 28.8 ± 5.5 | 31.3 ± 2.3 (P) | Oral tocolytics (92.3% received oral terbutaline) | 0% (0/353) | 0% (0/353) | 1 (0.02, 50.54)
Myocardial infarction | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Pulmonary edema | Lam,† (2003)^17^ | Retrospective cohort (n=558) | 27.4 ± 5.9 | 31.6 ± 2.2 (P) | Oral tocolytics (95.3% received oral terbutaline) | 0% (0/279) | 0.4% (1/279) | 0.33 (0.01, 8.19)
Pulmonary edema
Pulmonary edema | Lam,†,** (2001)^18^ | Retrospective cohort (n=706) | 28.8 ± 5.5 | 31.3 ± 2.3 (P) | Oral tocolytics (92.3% received oral terbutaline) | 0.3% (1/353) | 0% (0/353) | 3.01 (0.12, 74.11)
Refractory hypotension | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Therapy discontinuation | Morrison^†^ (2003)^12^ | Prospective cohort (n=60) | 25.6 ± 5.2 | 29.5 ± 2.3 (P) | No treatment | 0% (0/15) | N/A | N/A
Therapy discontinuation
Therapy discontinuation | Guinn (1998) ^9^ | RCT (n=52) | 21.6 ± 5.7 | 30.6 ± 2.8 (T) | Placebo | 45.8% (11/24) | 32.1% (9/28) | 1.79 (0.58, 5.52)
Withdrawal-AE | N/A | N/A | | | N/A | N/A | N/A | N/A

CI = confidence interval; GA = gestational age; GTT = glucose tolerance test; N/A = not applicable; NR = not reported; OR = odds ratio; RCT = randomized controlled trial; SQ = subcutaneous; Withdrawal-AE = withdrawal due to adverse effects

Note: Subjects were women with singleton gestation only, unless indicated otherwise.

* Either at preterm labor (indicated by P) or at start of subcutaneous terbutaline therapy (indicated by T). If study population stated RPTL as an inclusion criterion, then this is the gestational age at the episode of RPTL.

† Study population consisted exclusively of women with RPTL.

‡ Gestation not specified, although study population likely consisted of women with single and multiple gestation.

§ Data for a second comparison group, which consisted of women without preterm labor, was not extracted.

** Study population consisted exclusively of women with twin gestation.

Table F11 Studies that reported neonatal harms (Key Question 4)

Outcome | First Author (Year) | Study Design (n=Sample Size) | Mean Maternal Age (Years) | Mean GA (Weeks)^*^ | Comparator(s) | Results—SQ Terbutaline Pump: % (n/N) | Results—Comparison: % (n/N) | Results—OR (95% CI)
Hypoglycemia | Wenstrom^†^ (1997)^10^ | RCT (n=42) | 26.2 ± 5.3 | 30.4 ± 2.3 (T) | Placebo (C_1_) Oral terbutaline (C_2_) | 0% (0/19) | C_1_: 6.7% (1/15) C_2_: 0% (0/16) | 0.25 (0.01, 6.53) 0.85 (0.02, 45.03)
Hypocalcemia | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Ileus | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A

CI = confidence interval; GA = gestational age; N/A = not applicable; OR = odds ratio; RCT = randomized controlled trial; SQ = subcutaneous

* Either at preterm labor (indicated by P) or at start of subcutaneous terbutaline therapy (indicated by T). If study population stated RPTL as an inclusion criterion, then this is the gestational age at the episode of RPTL.

† Study population consisted of women with single and twin gestation. Denominator is number of infants.

Table F12 Criteria for rating level of maternal activity variables

Criteria | Low Activity Level | Normal Activity Level | High Activity Level
Marital Status | Married or living common-law with partner not working outside the home | Married or living common-law with partner working outside the home | Single, divorced, widowed, or separated
Working Status | Not working | Occasional or part-time work | Full-time work
Caring for Other Children in the Home^1^ | No other children in the home | One other child in the home | More than one other child in the home
Available Social Support | Women report substantial support from friends and family | Women report limited support to be available from friends and family | No support available to women from friends and family
Bed Rest | Complete bed rest with bathroom privileges only | Bed rest suggested when an increase in uterine contractions only | Bed rest not recommended
Restriction of Maternal Activities | Maternal activities, such as household chores and intercourse, recommended to be completely restricted | Restriction of activities suggested when an increase in uterine contractions only | No restriction of maternal activities recommended

Table F13 Risk of bias ratings for level of maternal activity

First Author (year) | Marital Status | Working Status | Caring for Other Children | Social Support | Bed Rest | Restriction of Maternal Activities | Overall Rating
RCTs
Guinn (1998) ^9^ | Not reported | Not reported | Multiparity: 57% of placebo group and 63% of terbutaline group | Not reported | Not reported | Not reported | UNCLEAR
Guinn (1998) ^9^ | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | UNCLEAR
Wenstrom (1997) ^10^ | Not reported | Not reported | Median parity provided for all groups | Not reported | Patients were instructed to remain at bed rest | Not reported | LOW Based on bed rest
Wenstrom (1997) ^10^ | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | LOW | INSUFFICIENT DATA TO MAKE RATING | LOW Based on bed rest
NONRANDOMIZED TRIALS
Lindenbaum (1992) ^11^ | Not reported | Not reported | Not reported | Not reported | Not reported | Not reported | UNCLEAR
Lindenbaum (1992) ^11^ | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | UNCLEAR
PROSPECTIVE COHORTS
Morrison (2003) ^12^ | Not reported | Not reported | Not reported | Not reported | Bed rest advised | Interdiction of intercourse advised | LOW
Morrison (2003) ^12^ | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | LOW | LOW | LOW
Morrison (1992) ^13^ | Not reported | Not reported | Parity reported | Not reported | Not reported | Not reported | UNCLEAR
Morrison (1992) ^13^ | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | UNCLEAR
RETROSPECTIVE COHORTS
Flick (2010) ^14^ | Married: 71.8% in nifedipine group and 85.3% in terbutaline group | Not reported | Not reported | Not reported | Not reported | Not reported | UNCLEAR
Flick (2010) ^14^ | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | UNCLEAR
de la Torre (2008) ^15^ | Married: 80.9% in nifedipine group and 87.8% in SQ terbutaline group | Not reported | Nulliparous: 56% in nifedipine group and 58.8% in SQ terbutaline group | Not reported | Not reported | Not reported | UNCLEAR
de la Torre (2008) ^15^ | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | UNCLEAR
Fleming (2004) ^16^ | Married: 71.8% in nifedipine group and 85.2% in SQ terbutaline group | Not reported | Nulliparous: 43% in nifedipine group and 40.8% in SQ terbutaline group | Not reported | Not reported | Not reported | UNCLEAR
Fleming (2004) ^16^ | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | UNCLEAR
Lam (2003) ^17^ | Married: 69.2% in oral tocolytic group and 84.2% in SQ terbutaline group | Not reported | Not reported | Not reported | Not reported | Not reported | UNCLEAR
Lam (2003) ^17^ | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | UNCLEAR
Lam (2001) ^18^ | Married: 77.3% in oral tocolytic group and 87.8% in SQ terbutaline group | Not reported | Not reported | Not reported | Not reported | Not reported | UNCLEAR
Lam (2001) ^18^ | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | UNCLEAR
Allbert (1994) ^19^ | Not reported | Not reported | Parity provided for oral terbutaline and SQ terbutaline groups | Not reported | Bed rest advised | Prohibition of intercourse advised | LOW
Allbert (1994) ^19^ | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | LOW | LOW | LOW
Regenstein (1993) ^20^ | Not reported | Not reported | Parity reported | Not reported | Not reported | Not reported | UNCLEAR
Regenstein (1993) ^20^ | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | UNCLEAR
CASE SERIES
Adkins (1993) ^21^ | Not reported | Not reported | Not reported | Not reported | If contractions were detected, patients were instructed to void, hydrate, remain at bed rest. | Not reported | LOW Based on bed rest
Adkins (1993) ^21^ | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | LOW | INSUFFICIENT DATA TO MAKE RATING | LOW Based on bed rest
Lam (1988) ^22^ | Not reported | Not reported | Not reported | Not reported | Patients were instructed to remain in bed, but were permitted bathroom privileges | Not reported | LOW Based on bed rest
Lam (1988) ^22^ | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | LOW | INSUFFICIENT DATA TO MAKE RATING | LOW Based on bed rest

RCT = randomized controlled trial; SQ = subcutaneous

Table F14 Criteria for rating level of maternal care variables

Criteria | Low Level of Care | Moderate Level of Care | High Level of Care
Nursing Assessments | No nursing assessment made | Patient questioned regarding any barriers to compliance with prescribed therapy | An in-person assessment at the patient's home to identify barriers to successful compliance of prescribed therapy
Home Uterine Activity Monitoring | No home uterine activity monitoring recommended | Home uterine activity monitoring recommended, with or without a monitor | Home uterine activity monitored and data sent via telephone or computer to a central care centre to be assessed by a trained health professional
Home Visits | No home visits provided | At least one home visit provided | Regular (e.g., weekly) home visits provided
Education About Preterm Labor | No education was provided Written or oral education on the signs and symptoms of preterm labor, possible adverse reactions to treatment, etc. | Written and oral education provided on signs and symptoms of preterm labor, possible adverse reactions to treatment, etc. | Written and oral education provided on signs and symptoms of preterm labor, possible adverse reactions to treatment, etc. and education was individualized.
Telephone Support | No telephone support available | Telephone support available during select hours of the day only | Telephone support available 24 hours a day, 7 days a week by trained health professionals
Restriction of Maternal Activities | No suggestions made by a health professional regarding restriction of maternal activities | Global recommendations for restriction of maternal activities made for all women | Individualized suggestions for restriction of maternal activities made based on each patient's condition

Table F15 Ratings for level of maternal care

First Author (Year) | Nursing Assessments | Home Uterine Activity Monitoring | Home Visits | Education About Preterm Labor | Telephone Support | Restriction of Maternal Activities | Other Cointerventions | Overall Rating
RCTs
Guinn (1998) ^9^ | Not reported | Not reported | Not reported | Educated about signs and symptoms of preterm labor “The women were also educated about early signs and symptoms of preterm labor” | Nursing support available 24 hours/day to answer questions and monitor therapy. | Not reported | Outpatients were followed up on a weekly basis until 36 weeks' gestation. | MODERATE
Guinn (1998) ^9^ | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | LOW | HIGH | INSUFFICIENT DATA TO MAKE RATING | MODERATE | MODERATE
Wenstrom (1997) ^10^ | Not reported | Not reported | Not reported | Not reported | Not reported | Patients were instructed to remain at bed rest | Patients seen in outpatient clinic weekly or biweekly | UNCLEAR
Wenstrom (1997) ^10^ | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | MODERATE | MODERATE | UNCLEAR
NONRANDOMIZED TRIALS
Lindenbaum (1992) ^11^ | Not reported | Not reported | Not reported | Not reported | Not reported | Not reported | Not reported | UNCLEAR
Lindenbaum (1992) ^11^ | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | UNCLEAR
PROSPECTIVE COHORTS
Morrison (2003) ^12^ | Verbal information received from John Morrison (March 24/11) A daily telephone call was made by a perinatal nurse. Subjects were questioned about the signs and symptoms of preterm labor (e.g., contraction, tightening, cervical changes) and were also asked open-ended questions. | Patients in terbutaline group received a uterine contraction monitor and were instructed to monitor twice daily. A daily telephone call by a perinatal nurse was done to gather this information. | Verbal information received from John Morrison (March 24/11) At least one home visit was made by a nurse to set up the SQ terbutaline pump. | Educated about the signs and symptoms of preterm labor “Women in the study and control groups were taught the signs and symptoms associated with preterm labor.” Verbal information received from John Morrison (March 24/11) Education also provided during daily calls by nurse. | Patients were given a 24-hour hotline number to call if they had any questions. | Bed rest and interdiction of intercourse advised. | Patients were followed up in a preterm birth prevention clinic. Verbal information received from John Morrison (March 24/11) Assessed for signs and symptoms of preterm labour and provided education: this was repeated every 1–2 weeks. During this time patients were also questioned further, education was reconfirmed, and more tests may have been performed. | PUMP GROUP: HIGH CONTROL: MODERATE
Morrison (2003) ^12^ | MODERATE | RATING CANNOT BE MADE DUE TO CONFOUNDING | MODERATE | LOW | HIGH | MODERATE | MODERATE | PUMP GROUP: HIGH CONTROL: MODERATE
Morrison (1992) ^13^ | Intensive perinatal nurse assessments were available Verbal information received from John Morrison (March 24/11) A daily telephone call was made by a perinatal nurse. Subjects were questioned about the signs and symptoms of preterm labor (e.g., contraction, tightening, cervical changes) and were also asked open-ended questions. (same as Morrison 2003) | Monitored uterine activity twice a day. | Verbal information received from John Morrison (March 24/11) At least one home visit was made by a nurse to set up the SQ terbutaline pump. | Verbal information received from John Morrison (March 24/11) Educated about the signs and symptoms of preterm labor “Women in the study and control groups were taught the signs and symptoms associated with preterm labor.” (same as Morrison 2003) Education also provided during daily calls by nurse. | Verbal information received from John Morrison (March 24/11) Patients were given a 24-hour hotline number to call if they had any questions. (same as Morrison 2003) | Verbal information received from John Morrison (March 24/11) Bed rest and interdiction of intercourse advised. (same as Morrison 2003) | Verbal information received from John Morrison (March 24/11) Assessed for signs and symptoms of preterm labour and provided education: this was repeated every 1–2 weeks. During this time patients were also questioned further, education was reconfirmed, and more tests may have been performed. (same as Morrison 2003) | MODERATE
Morrison (1992) ^13^ | MODERATE | MODERATE | MODERATE | LOW | HIGH | MODERATE | MODERATE | MODERATE
RETROSPECTIVE COHORTS
Flick (2010) ^14^ | To identify barriers to care or issues that may make it difficult for the patients to comply with plan of care. | An electronic device used to monitor minimum of twice per day and as needed for PTL symptoms. Data transmitted by telephone to a care center and interpreted by perinatal nurses. | Initial home visit by an experienced perinatal nurse to provide written and verbal education about condition. | Initial home visit by an experienced perinatal nurse to provide written and verbal education about condition. | Available 24 hours a day, 7 days a week, by perinatal nurses and pharmacists. | Not reported | Not reported | HIGH
Flick (2010) ^14^ | MODERATE | HIGH | MODERATE | HIGH | HIGH | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | HIGH
de la Torre (2008) ^15^ | Nursing assessment to identify barriers to care. | Patients monitored uterine contractions minimum of twice/day and as needed for PTL symptoms. This data was transmitted by telephone to a care center and interpreted by a perinatal nurse. | A perinatal nurse conducted an initial visit to each patient's home | A perinatal nurse conducted an initial visit to each patient's home to provide written and verbal education about her condition (review of signs and symptoms of preterm labor, medication compliance, adverse effects, electronic uterine contraction monitor, clinical protocols). | Telephone support by nurses and pharmacists available 24 hours/day 7 days/week. | Not reported | Not reported | HIGH
de la Torre (2008) ^15^ | HIGH | HIGH | MODERATE | HIGH | HIGH | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | HIGH
Fleming (2004) ^16^ | Adherence to the prescribed regimen was encouraged, assessed, and documented daily. | Uterine contraction data collected at least twice daily and were transmitted to a perinatal center staffed with nurses who evaluated the data and completed a telephone assessment of signs and symptoms. | Initial home visit and followup visits conducted as needed. | Individual patient teaching sessions with a nurse about the signs and symptoms of preterm labor. | Perinatal nurses were available 24 hours/day for 7 days/week for data evaluation, patient calls, and nursing support. | Not reported | Not reported | HIGH
Fleming (2004) ^16^ | MODERATE | HIGH | MODERATE | HIGH | HIGH | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | HIGH
Lam (2003) ^17^ | Daily nursing assessments of electronically transmitted uterine activity data and assessment of patients' clinical condition. The extent of adherence to the prescribed regimen was also assessed and adherence encouraged during each nurse-patient contact. | Use of a monitoring device for uterine contractions and data electronically transmitted. Information received from Fung Lam April 4/11 Uterine activity monitored twice daily and when needed. | Information received from Fung Lam April 4/11 Initial home visit by an experienced perinatal nurse to provide written and verbal education about condition. | Individual patient teaching sessions with a nurse about the signs and symptoms of preterm labor. | Nursing staff available at all times for patient phone calls. Information received from Fung Lam April 4/11 24/7 telephone support available. | Information received from Fung Lam April 4/11 Activity level was prescribed by each patient health care provider and not by the provider of outpatient services. Uterine contractions used to determine tolerated activity level. | Information received from Fung Lam April 4/11 Tocolysis adjusted for an increase in monitored uterine contractions. Frequency of physician office visits determined by each patient's health care provider. | HIGH
Lam (2003) ^17^ | MODERATE | HIGH | MODERATE | HIGH | HIGH | HIGH | INSUFFICIENT DATA TO MAKE RATING | HIGH
Lam (2001) ^18^ | Daily telephone nursing assessment of objective patient data and subjective symptoms. | Home uterine activity monitoring (no further details provided). Information received from Fung Lam April 4/11 Use of a monitoring device for uterine contractions and data electronically transmitted. Uterine activity monitored twice daily and when needed. | Information received from Fung Lam April 4/11 Initial home visit by an experienced perinatal nurse to provide written and verbal education about condition. | Educated about the signs and symptoms of preterm labor “This program included patient education regarding the signs and symptoms of preterm labor.” Information received from Fung Lam April 4/11 Initial home visit by an experienced perinatal nurse to provide written and verbal education about condition. | Daily telephone nursing assessment. Information received from Fung Lam April 4/11 24/7 telephone support available. | Information received from Fung Lam April 4/11 Activity level was prescribed by each patient healthcare provider and not by the provider of outpatient services. Uterine contractions used to determine tolerated activity level. | Information received from Fung Lam April 4/11 Tocolysis adjusted for an increase in monitored uterine contractions. Frequency of physician office visits determined by each patient's health care provider. | HIGH
Lam (2001) ^18^ | MODERATE | HIGH | MODERATE | HIGH | HIGH | HIGH | INSUFFICIENT DATA TO MAKE RATING | HIGH
Allbert (1994) ^19^ | Verbal information received from John Morrison (March 24/11) A daily telephone call was made by a perinatal nurse. Subjects were questioned about the signs and symptoms of preterm labor (e.g. contraction, tightening, cervical changes) and were also asked open-ended questions. (same as Morrison 2003) | Patients conducted home uterine contraction monitoring twice daily. | Home nursing care received by SQ terbutaline group, appears only in this group. Verbal information received from John Morrison (March 24/11) At least one home visit was made by a nurse to set up the SQ terbutaline pump. | Verbal information received from John Morrison (March 24/11) Educated about the signs and symptoms of preterm labor “Women in the study and control groups were taught the signs and symptoms associated with preterm labor.” (same as Morrison 2003) Education also provided during daily calls by nurse. | Daily phone contact by a perinatal nurse Verbal information received from John Morrison (March 24/11) Patients were given a 24 hour hotline number to call if they had any questions. (same as Morrison 2003) | Bed rest and prohibition of intercourse advised. | Verbal information received from John Morrison (March 24/11) Assessed for signs and symptoms of preterm labour and provided education: this was repeated every 1-2 weeks. During this time patients were also questioned further, education was reconfirmed, and more tests may have been performed. (same as Morrison 2003) | PUMP GROUP: HIGH CONTROL: MODERATE
Allbert (1994) ^19^ | MODERATE | MODERATE | RATING CANNOT BE MADE DUE TO POTENTIAL CONFOUNDING | LOW | HIGH | MODERATE | MODERATE | PUMP GROUP: HIGH CONTROL: MODERATE
Regenstein (1993) ^20^ | Not reported | Not reported | Study included women receiving home nursing care or care by perinatology service, so cannot be sure whether equal number of patients in oral and SQ terbutaline groups received home care. | Not reported | Not reported | Not reported | Not reported | UNCLEAR
Regenstein (1993) ^20^ | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | RATING CANNOT BE MADE DUE TO POTENTIAL CONFOUNDING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | INSUFFICIENT DATA TO MAKE RATING | UNCLEAR
CASE SERIES
Adkins (1993) ^21^ | Not reported | Uterine self-palpitation was taught as a method for detecting contractions twice daily. | Home infusion therapy nurse-clinician made an initial home visit. F/U care included: weekly appointments with physicians, frequent telephone calls from home infusion therapy nurse-clinician and physician's offices, and home visits as needed. | Patients educated about the signs and symptoms of preterm labor. “Patients received individual instruction from both physicians and nurses regarding the signs and symptoms of preterm labor.” | F/U care included: weekly appointments with physicians, frequent telephone calls from home infusion therapy nurse-clinician and physician's offices. | Bed rest recommended when there was an increase in uterine contractions. | Standard nonpharmacologic al interventions, such as bed rest and oral hydration, were a part of the therapeutic regimen. | MODERATE
Adkins (1993) ^21^ | INSUFFICIENT DATA TO MAKE RATING | MODERATE | MODERATE | HIGH | MODERATE | MODERATE | MODERATE | MODERATE
Lam (1988) ^22^ | Information received from Fung Lam April 4/11 Daily telephone nursing assessment of objective patient data and subjective symptoms. | Uterine activity was monitored at least twice daily and data was transmitted to study center. Information received from Fung Lam April 4/11 Home uterine activity monitoring. Use of a monitoring device for uterine contractions and data electronically transmitted. Uterine activity monitored twice daily and when needed. | Weekly followup home visits were carried out by perinatal nurses. Information received from Fung Lam April 4/11 Initial in-hospital and home visit by study nurse ( an experienced perinatal nurse) to provide written and verbal education about condition When patient was at home, there were weekly nursing home visits. | Information received from Fung Lam April 4/11 Educated about the signs and symptoms of preterm labor “This pilot program included patient education regarding the signs and symptoms of preterm labor.” Initial in-hospital and home visit by study nurse ( an experienced perinatal nurse) to provide written and verbal education about condition When patient was at home, there were weekly nursing home visits. | Information received from Fung Lam April 4/11 Daily telephone nursing assessment by study nurse. 24/7 telephone support available. | Patients were instructed to remain in bed, but were permitted bathroom privileges. Information received from Fung Lam April 4/11 Activity level was prescribed by study physiciand There were no providers of terbutaline pump outpatient services at this time. Uterine contractions used to determine tolerated activity level. | Patients noted their perceived uterine activity on daily preterm labor logs. Information received from Fung Lam April 4/11 Activity level was prescribed by study physiciand There were no providers of terbutaline pump outpatient services at this time. Uterine contractions used to determine tolerated activity level. | HIGH
Lam (1988) ^22^ | MODERATE | HIGH | HIGH | HIGH | HIGH | HIGH | HIGH | HIGH

RCT = randomized controlled trial; SQ = subcutaneous

Table F16 Studies that reported pump-related outcomes (Key Question 6)

Outcome | First Author (Year) | Study Design (n=Sample Size) | Mean Maternal Age (Years) | Mean GA (Weeks)^*^ | Comparator(s) | Results—SQ Terbutaline Pump: % (n/N) | Results—Comparison: % (n/N) | Results—OR (95% CI)
Dislodgment | Adkins (1993) ^21^ | Case series (n=51) | 31.0 ± 4.0 | 29.1 ± 3.6 (T) | No comparator | 2.0% (1/51) | N/A | (exact central CI, 0.5%, 10%)
Missed doses | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Overdose | N/A | N/A | N/A | N/A | N/A | N/A | N/A | N/A
Other:
Infusion site infection | Lam (1988) ^22^ | Case series (n=9) | NR | 29.6 ± 3.7 (T) | No comparator | 0% (0/9) | N/A | N/A
Local pain | Wenstrom (1997) ^10^ | RCT (n=42) | 26.2 ± 5.3 | 30.4 ± 2.3 (T) | Placebo (C_1_) Oral terbutaline (C_2_) | 13.3% (2/15) | C_1_:17% (2/12) C_2_: 0% (0/15) | 0.77 (0.09, 6.45) 5.74 (0.25, 130.38)
Local skin irritation | Wenstrom (1997) ^10^ | RCT (n=42) | 26.2 ± 5.3 | 30.4 ± 2.3 (T) | Placebo (C_1_) Oral terbutaline (C_2_) | 6.7% (1/15) | C_1_: 0% (0/12) C_2_: 0% (0/15) | 2.59 (0.10, 69.34) 3.21 (0.12, 85.21)
Pump malfunction/mechanical failures and complications | Lam (1988) ^22^ | Case series (n=9) | NR | 29.6 ± 3.7 (T) | No comparator | 0% (0/9) | N/A | N/A
Pump malfunction/mechanical failures and complications | Adkins (1993) ^21^ | Case series (n=51) | 31.0 ± 4.0 | 29.1 ± 3.6 (T) | No comparator | 2.0% (1/51) | N/A | (exact central CI, 0.5%, 10%)

CI = confidence interval; GA = gestational age; N/A = not applicable; NR = not reported; OR = odds ratio; RCT = randomized controlled trial; SQ = subcutaneous

* Either at preterm labor (indicated by P) or at start of subcutaneous terbutaline therapy (indicated by T). If study population stated RPTL as an inclusion criterion, then this is the gestational age at the episode of RPTL.