# Excluded Studies

## Level 1 exclusions (n=215)

Adamcova M, Kokstein Z, Palicka V, et al. Cardiac troponin T in neonates after acute and long-term tocolysis. Biology of the Neonate. 2000;78(4):288-92. [pmid: 11093008].
Adzick NS, Sutton LN, Crombleholme TM, et al. Successful fetal surgery for spina bifida. Lancet. 1998;352(9141):1675-6. [pmid: 9853442].
Anderson KE, Bengtsson LP, Gustafson I, et al. The relaxing effect of terbutaline on the human uterus during term labor. American Journal of Obstetrics & Gynecology. Mar. 1. 1975;121(5):602-9. [pmid: 1115162].
Anotayanonth S, Subhedar NV, Garner P, et al. Betamimetics for inhibiting preterm labor. Cochrane Database Syst Rev. 2004;(4):CD004352. [pmid: 15495104].
Arias F. Intrauterine resuscitation with terbutaline: a method for the management of acute intrapartum fetal distress. Am J Obstet Gynecol. May. 1. 1978;131(1):39-43. [pmid: 645781].
Athanassiou AM, Turrentine MA. Myocardial infarction and coronary artery dissection during pregnancy associated with type IV Ehlers-Danlos syndrome. American Journal of Perinatology. Apr. 1996;13(3):181-3. [pmid: 8688112].
Ayromlooi J, Desiderio DM, Tobias M. Terbutaline-induced changes in ovine, fetal and maternal hemodynamics, and fetal electroencephalogram. Pediatric Pharmacology. 1981;1(4):321-30. [pmid: 6810294].
Ayromlooi J, Desiderio DM, Tobias MD, et al. Isoxsuprine-induced changes in maternal and fetal hemodynamics and fetal electroencephalogram. Drug Development Research. 1982;2(1):55-64.
Barnett AH, Stubbs SM, Mander AM. Management of premature labor in diabetic pregnancy. Diabetologia. 1980;18(5):365-8. [pmid: 6107256].
Bergman B, Bokstrom H, Borga O, et al. Transfer of terbutaline across the human placenta in late pregnancy. Eur J Respir Dis Suppl. 1984;134:81-6. [pmid: 6586489].
Berkman ND, Thorp JM Jr, Lohr KN, et al. Tocolytic treatment for the management of preterm labor: a review of the evidence. Am J Obstet Gynecol. Jun. 2003;188(6):1648-59. [pmid: 12825006].
Bernstein IM, Catalano PM. Ketoacidosis in pregnancy associated with the parenteral administration of terbutaline and betamethasone. A case report. Journal of Reproductive Medicine. Aug. 1990;35(8):818-20. [pmid: 2120435].
Besinger RE, Niebyl JR. The safety and efficacy of tocolytic agents for the treatment of preterm labor. Obstet Gynecol Surv. Jul. 1990;45(7):415-40. [pmid: 2195409].
Besinger RE, Niebyl JR, Keyes WG, et al. Randomized comparative trial of indomethacin and ritodrine for the long-term treatment of preterm labor. American Journal of Obstetrics & Gynecology. Apr. 1991;164(4):981-6. [pmid: 2014850].
Bhat N, Seifer D, Hensleigh P. Paradoxical response to intravenous terbutaline. American Journal of Obstetrics and Gynecology. 1985;153(3):310-1. [pmid: 4050897].
Bhide A. Oral nifepidine versus subcutaneous terbutaline tocolysis for external cephalic version: A double-blind randomised trial -Commentary. BJOG : An International Journal of Obstetrics and Gynaecology. 2009;116(1):80-1.
Bivins HA Jr, Newman RB, Fyfe DA, et al. Randomized trial of oral indomethacin and terbutaline sulfate for the long-term suppression of preterm labor. Am J Obstet Gynecol. Oct. 1993;169(4):1065-70. [pmid: 8238121].
Blackstone J. Effects of tocolytics on the fetal heart. Journal of Maternal -Fetal Investigation. 1996;6(3):158-62.
Bloss JD, Hankins GD, Gilstrap LC III, et al. Pulmonary edema as a delayed complication of ritodrine therapy. A case report. Journal of Reproductive Medicine. Jun. 1987;32(6):469-71. [pmid: 3612639].
Boehm FH, Lombardi SJ, Rosemond RL. Immediate cerclage following delivery of one nonviable twin: A report of three cases. Journal of Reproductive Medicine for the Obstetrician and Gynecologist. 1992;37(12):986-8. [pmid: 1287211].
Boog G, Brahim MB, Gandar R. Beta-mimetic drugs and possible prevention of respiratory distress syndrome. Br J Obstet Gynaecol. Apr. 1975;82(4):285-8. [pmid: 235939].
Borberg C, Gillmer MD, Beard RW, et al. Metabolic effects of beta-sympathomimetic drugs and dexamethasone in normal and diabetic pregnancy. Br J Obstet Gynaecol. Mar. 1978;85(3):184-9. [pmid: 24459].
Braden GL, von Oeyen PT, Germain MJ, et al. Ritodrine- and terbutaline-induced hypokalemia in preterm labor: mechanisms and consequences. Kidney International. Jun. 1997;51(6):1867-75. [pmid: 9186877].
Bremme K, Eneroth P, Carsjo BM, et al. Blood pressure regulation in third-trimester pregnant women receiving tocolytic terbutaline infusion. European Journal of Obstetrics, Gynecology, & Reproductive Biology. Oct. 1986;23(1-2):53-60.
Bremme K, Eneroth P, Nordstrom L, et al. Effects of infusion of the beta-adrenoceptor agonist terbutaline on serum magnesium in pregnant women. Magnesium. 1986;5(2):85-94. [pmid: 3713256].
Bricker L, Peden H, Tomlinson AJ, et al. Titrated low-dose vaginal and/or oral misoprostol to induce labor for prelabor membrane rupture: A randomised trial. BJOG : An International Journal of Obstetrics and Gynaecology. 2008;115(12):1503-11. [pmid: 18752586].
Brittain C, Carlson JW, Gehlbach DL, et al. A case report of massive vulvar edema during tocolysis for preterm labor. American Journal of Obstetrics and Gynecology. 1991;165(2):420-2. [pmid: 1872351].
Brown HL, Hiett AK, Britton KA, et al. Tocolytic treatment for preterm contractions with and without cervical changes. American Journal of Perinatology. Aug. 1997;14(7):405-9. [pmid: 9263560].
Brown SM, Tejani NA. Terbutaline sulfate in the prevention of recurrence of premature labor. Obstetrics & Gynecology. Jan. 1981;57(1):22-5. [pmid: 7005777].
Cabar FR, Bittar RE, Gomes CM, et al. [Atosiban as a tocolytic agent: a new proposal of a therapeutic approach]. [Portuguese]. Revista Brasileira de Ginecologia e Obstetricia. Feb. 2008;30(2):87-92. [pmid: 19142481].
Caritis SN. Treatment of preterm labor. A review of the therapeutic options. Drugs. Sep. 1983;26(3):243-61. [pmid: 6137355].
Caritis SN, Darby MJ, Chan L. Pharmacologic treatment of preterm labor. Clinical Obstetrics and Gynecology. 1988;31(3):635-51. [pmid: 3066546].
Caritis SN, Edelstone DI, Mueller-Heubach E. Pharmacologic inhibition of preterm labor. Am J Obstet Gynecol. Mar. 1. 1979;133(5):557-78. [pmid: 35978].
Caritis SN, Morishima HO, Stark RI, et al. Effects of terbutaline on the pregnant baboon and fetus. Obstetrics & Gynecology. Jul. 1977;50(1):56-60. [pmid: 876523].
Caritis SN, Mueller-Heubach E, Morishima HO, et al. Effect of terbutaline on cardiovascular state and uterine blood flow in pregnant ewes. Obstetrics & Gynecology. Nov. 1977;50(5):603-6. [pmid: 909668].
Caritis SN, Toig G, Heddinger LA, et al. A double-blind study comparing ritodrine and terbutaline in the treatment of preterm labor. American Journal of Obstetrics & Gynecology. Sep. 1. 1984;150(1):7-14. [pmid: 6383045].
Carlan SJ, Dent JM, Huckaby T, et al. The effect of epidural anesthesia on safety and success of external cephalic version at term. Anesthesia and Analgesia. 1994;79(3):525-8. [pmid: 8067558].
Carstensen MH, Bahnsen J, Sterzing E. [Tocolysis with beta sympathomimetics alone or combined with the calcium antagonist verapamil? Influence of verapamil on the fetus]. Geburtshilfe Frauenheilkd. Aug. 1983;43(8):481-5. [pmid: 6555114].
Chandiramani M, Shennan A. Preterm labor: update on prediction and prevention strategies. Curr Opin Obstet Gynecol. Dec. 2006;18(6):618-24. [pmid: 17099332].
Chauhan SP, Rutherford SE, Hess LW, et al. Prophylactic intrapartum amnioinfusion for patients with oligohydramnios. A prospective randomized study. Journal of Reproductive Medicine. Sep. 1992;37(9):817-20. [pmid: 1453405].
Chimura T, Mitsui T, Inoue K. [Beta 1-, beta 2-effects of ritrodine and terbutaline in the treatment of preterm labor (author's transl)]. [Japanese]. Nippon Sanka Fujinka Gakkai Zasshi - Acta Obstetrica et Gynaecologica Japonica. Oct. 1981;33(10):1629-34.
Chung MY, Huang CB. Hyperkalemia in premature infants weighing less than 1,500 grams. Clinical Neonatology. 1999;6(1):1-5.
Collaris R, Tan PC. Oral nifepidine versus subcutaneous terbutaline tocolysis for external cephalic version: a double-blind randomised trial. BJOG : An International Journal of Obstetrics & Gynaecology. Jan. 2009;116(1):74-80. [pmid: 19087079].
Conde-Agudelo A, Romero R, Kusanovic JP. Nifedipine in the management of preterm labor: A systematic review and metaanalysis. American Journal of Obstetrics and Gynecology. 2011;(2):134. [pmid: 21284967].
Cotton DB, Strassner HT, Hill LM, et al. Comparison of magnesium sulfate, terbutaline and a placebo for inhibition of preterm labor. A randomized study. J Reprod Med. Feb. 1984;29(2):92-7. [pmid: 6708033].
Cowan M. Home care of the pregnant woman using terbutaline. [Review] [41 refs]. MCN, American Journal of Maternal Child Nursing. Mar. 1993;18(2):99-105.
Creasy RK. Preterm birth prevention: where are we?. Am J Obstet Gynecol. Apr. 1993;168(4):1223-30. [pmid: 8475969].
Dagbjartsson A, Herbertsson G, Stefansson TS, et al. Beta-adrenoceptor agonists and hypoxia in sheep fetuses. Acta Physiologica Scandinavica. Oct. 1989;137(2):291-9. [pmid: 2618763].
Davies AE, Robertson MJS. Pulmonary oedema after the administration of intravenous salbutamol and ergometrine. Case report. British Journal of Obstetrics and Gynaecology. 1980;87(6):539-41. [pmid: 7397088].
De Albuquerque PB, Spallicci MDB, Zugaib M. The control of premature labor. University Hospital of the Sao Paulo University. [Portuguese]. Revista Brasileira de Medicina. 2002;59(4):277-82.
De VM, Porto M, Major CA, et al. Tocolysis in advanced preterm labor: Impact on neonatal outcome. American Journal of Perinatology. 1995;12(4):294-8. [pmid: 7575840].
Dodd JM, Crowther CA, Dare MR, et al. Oral betamimetics for maintenance therapy after threatened preterm labor. [Review] [45 refs]. Cochrane Database of Systematic Reviews. 2006;(1):CD003927. 2006. [pmid: 16437467].
Domenichini Y, Thoulon JM. The cardiovascular complications of the use of betamimetic drugs in obstetrics. [French]. Journal de Gynecologie Obstetrique et Biologie de la Reproduction. 1982;11(7):861-7.
Egarter CH, Husslein PW, Rayburn WF. Uterine hyperstimulation after low-dose prostaglandin E2 therapy: tocolytic treatment in 181 cases. American Journal of Obstetrics & Gynecology. Sep. 1990;163(3):794-6. [pmid: 1976296].
Ekelund L, Enhorning G. Glucocorticoids and beta-adrenergic-receptor agonists: their combined effect on fetal rabbit lung surfactant. American Journal of Obstetrics & Gynecology. Aug. 15. 1985;152(8):1063-7. [pmid: 3839627].
El-Sayed Y, Pullen K, Riley ET, et al. Randomized comparison of intravenous nitroglycerin and subcutaneous terbutaline for external cephalic version under tocolysis. Am J Obstet Gynecol. Dec. 2004;191(6):2051-5. [pmid: 15592291].
Elliott JP. Management of high-order multiple gestation. [Review] [46 refs]. Clinics in Perinatology. 2005;32(2):387-402. [pmid: 15922789].
Elliott JP, Radin TG. The effect of corticosteroid administration on uterine activity and preterm labor in high order multiple gestations. Obstetrics and Gynecology. 1995;85(2):250-4. [pmid: 7824240].
Epstein MF, Nicholls E, Stubblefield PG. Neonatal hypoglycemia after beta-sympathomimetic tocolytic therapy. J Pediatr. Mar. 1979;94(3):449-53. [pmid: 423035].
Eronen M. The hemodynamic effects of antenatal indomethacin and a beta-sympathomimetic agent on the fetus and the newborn: a randomized study. Pediatr Res. Jun. 1993;33(6):615-9. [pmid: 8378121].
Eronen M, Pesonen E, Kurki T, et al. The effects of indomethacin and a beta-sympathomimetic agent on the fetal ductus arteriosus during treatment of premature labor: a randomized double-blind study. Am J Obstet Gynecol. Jan. 1991;164(1 Pt 1):141-6. [pmid: 1986601].
Faidley CK, Dix PM, Morgan MA, et al. Electrocardiographic abnormalities during ritodrine administration. Southern Medical Journal. May. 1990;83(5):503-6. [pmid: 2343328].
Ferguson JE II, Hensleigh PA, Kredenster D. Adjunctive use of magnesium sulfate with ritodrine for preterm labor tocolysis. American Journal of Obstetrics and Gynecology. 1984;148(2):166-71. [pmid: 6362416].
Fernandez CO, Bloom SL, Smulian JC, et al. A randomized placebo-controlled evaluation of terbutaline for external cephalic version. Obstetrics & Gynecology. Nov. 1997;90(5):775-9. [pmid: 9351763].
Fiascone JM, Rhodes TT, Grandgeorge SR, et al. Bronchopulmonary dysplasia: A review for the pediatrician. Current Problems in Pediatrics. 1989;19(4):169-227. [pmid: 2543540].
Fletcher SE, Fyfe DA, Case CL, et al. Myocardial necrosis in a newborn after long-term maternal subcutaneous terbutaline infusion for suppression of preterm labor. [see comment]. American Journal of Obstetrics & Gynecology. Nov. 1991;165(5 Pt 1):1401-4. [pmid: 1843619].
Fox MD, Allbert JR, McCaul JF, et al. Neonatal morbidity between 34 and 37 weeks' gestation. J Perinatol. Sep. 1993;13(5):349-53. [pmid: 8263618].
Fox NS, Gelber SE, Kalish RB, et al. Contemporary practice patterns and beliefs regarding tocolysis among U.S. maternal-fetal medicine specialists. Obstetrics and Gynecology. 2008;112(1):42-7. [pmid: 18591306].
Freda MC. Commentary on Home care of the pregnant woman using terbutaline. [original article by Cowan M appears in MCN 1993;18(2):99-105]. AWHONN's Women's Health Nursing Scan. Nov. 1993;7(6):20-1.
Freysz H, Willard D, Lehr A, et al. A long term evaluation of infants who received a beta-mimetic drug while in utero. J Perinat Med. 1977;5(2):94-9. [pmid: 894466].
Fuchs F. Prevention of premature birth. Clin Perinatol. Mar. 1980;7(1):3-15. [pmid: 6105033].
Gemelli M, De LF, Manganaro R, et al. Transient electrocardiographic changes suggesting myocardial ischaemia in newborn infants following tocolysis with beta-sympathomimetics. Eur J Pediatr. Jul. 1990;149(10):730-3. [pmid: 1976519].
Gjerdingen DK. Premature labor, Part II: Management. J Am Board Fam Pract. Nov. 1992;5(6):601-15. [pmid: 1462794].
Glock JL, Morales WJ. Efficacy and safety of nifedipine versus magnesium sulfate in the management of preterm labor: a randomized study. American Journal of Obstetrics & Gynecology. Oct. 1993;169(4):960-4. [pmid: 8238157].
Graber EA. Dilemmas in the pharmacological management of preterm labor. Obstet Gynecol Surv. Jul. 1989;44(7):512-7. [pmid: 2662077].
Graham G, Baxi L, Tharakan T. Laparoscopic cholecystectomy during pregnancy: A case series and review of the literature. Obstetrical and Gynecological Survey. 1998;53(9):566-74. [pmid: 9751939].
Guernsey BG, Villarreal Y, Snyder MD, et al. Pulmonary edema associated with the use of betamimetic agents in preterm labor. American Journal of Hospital Pharmacy. Dec. 1981;38(12):1942-8. [pmid: 6119903].
Guilliams S, Held B. Contemporary management and conduct of preterm labor and delivery: a review. Obstet Gynecol Surv. Mar. 1979;34(3):248-55. [pmid: 372871].
Guinn DA, Goepfert AR, Owen J, et al. Management options in women with preterm uterine contractions: a randomized clinical trial. American Journal of Obstetrics & Gynecology. Oct. 1997;177(4):814-8. [pmid: 9369825].
Gyetvai K, Hannah ME, Hodnett ED, et al. Tocolytics for preterm labor: a systematic review. Obstet Gynecol. Nov. 1999;94(5 Pt 2):869-77. [pmid: 10546776].
Haas DM, Imperiale TF, Kirkpatrick PR, et al. Tocolytic therapy: a meta-analysis and decision analysis. Obstet Gynecol. Mar. 2009;113(3):585-94. [pmid: 19300321].
Hallak M, Moise K Jr, Lira N, et al. The effect of tocolytic agents (indomethacin and terbutaline) on fetal breathing and body movements: a prospective, randomized, double-blind, placebo-controlled clinical trial. Am J Obstet Gynecol. Oct. 1992;167(4 Pt 1):1059-63. [pmid: 1415392].
Han S, Crowther CA, Moore V. Magnesium maintenance therapy for preventing preterm birth after threatened preterm labour. [Review] [27 refs][Update of Cochrane Database Syst Rev. 2000;(2):CD000940; PMID: 10796222]. Cochrane Database of Systematic Reviews. 2010;(7):CD000940. [pmid: 20614423].
Hawkins JL. Epidural analgesia for labor and delivery. New England Journal of Medicine. 2010;(16):1503-10. [pmid: 20410515].
Herbst A, Nilsson C. Diagnosis of early preterm labor. BJOG : An International Journal of Obstetrics and Gynaecology. 2006;113(SUPPL. 3):60-7. [pmid: 17206967].
Herbst A, Wide-Swensson D, Ingemarsson I. Significant delay of birth in advanced preterm labor at 23 gestational weeks with an oxytocin antagonist. European Journal of Obstetrics, Gynecology, & Reproductive Biology. May. 1. 2003;108(1):109-10.
Herskowitz A, Herskowitz B. Acute paraparesis due to terbutaline sulfate. South Med J. Feb. 2002;95(2):275-6. [pmid: 11846262].
Higby K, Xenakis EM, Pauerstein CJ. Do tocolytic agents stop preterm labor? A critical and comprehensive review of efficacy and safety. Am J Obstet Gynecol. Apr. 1993;168(4):1247-56. [pmid: 8097367].
Hill WC. Risks and complications of tocolysis. Clin Obstet Gynecol. Dec. 1995;38(4):725-45. [pmid: 8616971].
Hudgens DR, Conradi SE. Sudden death associated with terbutaline sulfate administration. [see comment]. American Journal of Obstetrics & Gynecology. Jul. 1993;169(1):120-1. [pmid: 8333435].
Hueston WJ. Prevention and treatment of preterm labor. American Family Physician. 1989;40(5):139-46. [pmid: 2683688].
Hueston WJ. A critical assessment of preterm labor prevention strategies. J Fam Pract. Jul. 1992;35(1):81-9. [pmid: 1613478].
Iams JD, Johnson FF, Creasy RK. Prevention of preterm birth. Clin Obstet Gynecol. Sep. 1988;31(3):599-615. [pmid: 3066545].
Ibrahim H, Kahn E, Harper RG, et al. Erythropoietin (EPO) levels in fetal rats after ritodrine and terbutaline administration. Biochemical Medicine and Metabolic Biology. 1994;52(2):128-31. [pmid: 7993659].
Ingemarsson I. Pharmacology of tocolytic agents. Clin Obstet Gynaecol. Aug. 1984;11(2):337-51. [pmid: 6148167].
Ingemarsson I, Arulkumaran S, Kottegoda SR. Complications of beta-mimetic therapy in preterm labor. Aust N Z J Obstet Gynaecol. Aug. 1985;25(3):182-9. [pmid: 2867757].
Jacquemyn Y. Use of tocolytics: What is the benefit of gaining even more time?. BJOG : An International Journal of Obstetrics and Gynaecology. 2006;113(SUPPL. 3):78-80. [pmid: 17206970].
Jiang J, Hu J, Bai C. Role of aquaporin and sodium channel in pleural water movement. Respiratory Physiology & Neurobiology. Dec. 16. 2003;139(1):83-8. [pmid: 14637313].
Johnson P. Suppression of preterm labor: Current concepts. Drugs. 1993;45(5):684-92. [pmid: 7686464].
Johnson WL, Harbert GM, Martin CB. Pharmacologic control of uterine contractility. In vitro human and in vivo monkey studies. Am J Obstet Gynecol. Oct. 15. 1975;123(4):364-75. [pmid: 241259].
Jovanovic R. Serial serum potassium and glucose levels during treatment of premature labor with oral terbutaline. International Journal of Gynaecology & Obstetrics. Oct. 1985;23(5):399-404. [pmid: 2866991].
Kanai M, Davies P, von AD, et al. Lung growth induced by prenatal tracheal occlusion and its modifying factors: A study in the rat model of congenital diaphragmatic hernia. Journal of Pediatric Surgery. 2001;36(2):251-9. [pmid: 11172410].
Kast A, Hermer M. Beta-adrenoceptor tocolysis and effects on the heart of fetus and neonate: A review. Journal of Perinatal Medicine. 1993;21(2):97-106. [pmid: 8099953].
Keirse MJ. A survey of tocolytic drug treatment in preterm labor. British Journal of Obstetrics & Gynaecology. May. 1984;91(5):424-30. [pmid: 6144322].
Keirse MJ. New perspectives for the effective treatment of preterm labor. Am J Obstet Gynecol. Aug. 1995;173(2):618-28. [pmid: 7645643].
King JF, Grant A, Keirse MJ, et al. Betamimetics in preterm labor: an overview of the randomized controlled trials. Br J Obstet Gynaecol. Mar. 1988;95(3):211-22. [pmid: 2897207].
Kitano Y, Kanai M, Davies P, et al. BAPS prize-1999: Lung growth induced by prenatal tracheal occlusion and its modifying factors: a study in the rat model of congenital diaphragmatic hernia. Journal of Pediatric Surgery. Feb. 2001;36(2):251-9. [pmid: 11172410].
Kobayashi H, Mizutani S, Wright JW. Placental leucine aminopeptidase- and aminopeptidase A-deficient mice offer insight concerning the mechanisms underlying preterm labor and preeclampsia. Journal of Biomedicine and Biotechnology. 2011. Article Number: 286947.
Kosasa TS, Busse R, Wahl N, et al. Long-term tocolysis with combined intravenous terbutaline and magnesium sulfate: a 10-year study of 1000 patients. Obstetrics & Gynecology. Sep. 1994;84(3):369-73. [pmid: 8058233].
Kramer MS. Preventing preterm birth: are we making any progress?. Yale J Biol Med. May. 1997;70(3):227-32. [pmid: 9544493].
Kramer WB, Saade GR, Belfort M, et al. A randomized double-blind study comparing the fetal effects of sulindac to terbutaline during the management of preterm labor. Am J Obstet Gynecol. Feb. 1999;180(2 Pt 1):396-401. [pmid: 9988808].
Kuczkowski KM, Benumof JL. Rebound hyperkalemia after cessation of intravenous tocolytic therapy with terbutaline in the treatment of preterm labor: anesthetic implications. [see comment]. Journal of Clinical Anesthesia. Aug. 2003;15(5):357-8. [pmid: 14507561].
Kurzel RB, Ott J. Cerclage, tocolysis and antibiotics for premature rupture of the membranes in previable twins: A case report. Journal of Reproductive Medicine for the Obstetrician and Gynecologist. 1992;37(3):289-90. [pmid: 1564718].
Lam F, Elliott J, Jones JS, et al. Clinical issues surrounding the use of terbutaline sulfate for preterm labor. [Review] [99 refs]. Obstetrical & Gynecological Survey. Nov. 1998;53(11 Suppl):S85-S95. [pmid: 9812326].
Lam F, Gill P. beta-Agonist tocolytic therapy. [Review] [114 refs]. Obstetrics & Gynecology Clinics of North America. Sep. 2005;32(3):457-84. [pmid: 16125044].
Lamont RF. The management of preterm labor. Clin Obstet Gynaecol. Jun. 1986;13(2):231-46. [pmid: 2873915].
Leonardi MR, Hankins GDV. What's new in tocolytics. Clinics in Perinatology. 1992;19(2):367-84. [pmid: 1352193].
Levav AL, Chan L, Wapner RJ. Long-term magnesium sulfate tocolysis and maternal osteoporosis in a triplet pregnancy: a case report. American Journal of Perinatology. Jan. 1998;15(1):43-6. [pmid: 9475687].
Lewis R, Mercer BM, Salama M, et al. Oral terbutaline after parenteral tocolysis: a randomized, double-blind, placebo-controlled trial. American Journal of Obstetrics & Gynecology. Oct. 1996;175(4 Pt 1):834-7. [pmid: 8885731].
Lipshitz J. Use of a beta 2-sympathomimetic drug as a temporizing measure in the treatment of acute fetal distress. Am J Obstet Gynecol. Sep. 1. 1977;129(1):31-6. [pmid: 900165].
Ljungstrom B, Mamsen A, Secher NJ. Indications for tocolytic therapy: incidence of true preterm labor with uterine contractions as the sole deciding factor. Am J Perinatol. Apr. 1989;6(2):218-21. [pmid: 2785389].
Lyrenas S, Grahnen A, Lindberg B, et al. Pharmacokinetics of terbutaline during pregnancy. European Journal of Clinical Pharmacology. 1986;29(5):619-23. [pmid: 3956566].
Macones GA, Sehdev HM, Berlin M, et al. Evidence for magnesium sulfate as a tocolytic agent. Obstetrical and Gynecological Survey. 1997;52(10):652-8. [pmid: 9326758].
Magann EF, Cleveland RS, Dockery JR, et al. Acute tocolysis for fetal distress: terbutaline versus magnesium sulphate. Australian & New Zealand Journal of Obstetrics & Gynaecology. Nov. 1993;33(4):362-4. [pmid: 8179541].
Magann EF, Norman PF, Bass JD, et al. Acute tocolysis for suspected intrapartum fetal distress: maternal effects of terbutaline versus magnesium sulfate. International Journal of Obstetric Anesthesia. Jul. 1995;4(3):140-4. [pmid: 15636996].
Mancuso KM, Yancey MK, Murphy JA, et al. Epidural analgesia for cephalic version: A randomized trial. Obstetrics and Gynecology. 2000;95(5):648-51. [pmid: 10775722].
Marsal K, Fisk NM, Calder AA, et al. The oxytocin antagonist atosiban versus the beta-agonist terbutaline in the treatment of preterm labor. A randomized, double-blind, controlled study. Acta Obstetricia et Gynecologica Scandinavica. 2001;80(5):413-22. [pmid: 11328217].
McCombs J. Update on tocolytic therapy. [Review] [68 refs]. Annals of Pharmacotherapy. May. 1995;29(5):515-22. [pmid: 7655136].
Meirowitz NB, Ananth CV, Smulian JC, et al. Value of maintenance therapy with oral tocolytics: a systematic review. [Review] [11 refs]. Journal of Maternal -Fetal Medicine. Jul. 1999;8(4):177-83. [pmid: 10406302].
Menticoglou SM, Morrison I, Harman CR, et al. Maximum possible impact of tocolytics in preventing preterm birth: a retrospective assessment. Am J Perinatol. Sep. 1992;9(5-6):394-7. [pmid: 1418142].
Mercer BM, Merlino AA. Magnesium sulfate for preterm labor and preterm birth. Obstetrics and Gynecology. 2009;114(3):650-68. [pmid: 19701047].
Moravec MA, Hurlbert BJ. Hypokalemia associated with terbutaline administration in obstetrical patients. Anesthesia & Analgesia. Dec. 1980;59(12):917-20. [pmid: 6108735].
Motazedian S, Ghaffarpasand F, Mojtahedi K, et al. Terbutaline versus salbutamol for suppression of preterm labor: a randomized clinical trial. Ann Saudi Med. Sep. 2010;30(5):370-5. [pmid: 20697169].
Neiger R, Star J. Hyperglycemia in non-diabetic gravidas receiving steroids for induction of fetal lung maturation. Journal of Maternal -Fetal Investigation. 1997;7(2):89-91.
Niebyl JR. Drugs for inhibition of premature labor. Clin Perinatol. Mar. 1979;6(1):53-63. [pmid: 38929].
O'Grady JP, Veille JC, Holland RL, et al. External cephalic version: A clinical experience. Journal of Perinatal Medicine. 1986;14(3):189-96. [pmid: 3537268].
O'Leary JA. Prophylactic tocolysis of twins. Am J Obstet Gynecol. Apr. 1986;154(4):904-5. [pmid: 3963080].
Olofsson P, Rydhstrom H, Sjoberg NO. How Swedish obstetricians manage premature rupture of the membranes in preterm gestations. American Journal of Obstetrics and Gynecology. 1988;159(5):1028-34. [pmid: 3189433].
Ostermann M, Porreco RP. Urgent cerclage at advanced cervical dilatation. Journal of Maternal -Fetal Investigation. 1993;2(6):279-82.
Pacheco LD, Rosen MP, Gei AF, et al. Management of uterine hyperstimulation with concomitant use of oxytocin and terbutaline. American Journal of Perinatology. Aug. 2006;23(6):377-80. [pmid: 16847795].
Palmer BS. The pharmacist's role in developing a critical pathway for preterm labor management. Journal of Pharmacy Practice. 1997;10(6):379-82.
Papke KR. Management of preterm labor and prevention of premature delivery. Nurs Clin North Am. Jun. 1993;28(2):279-88. [pmid: 8516173].
Parilla BV, Dooley SL, Minogue JP, et al. The efficacy of oral terbutaline after intravenous tocolysis. American Journal of Obstetrics & Gynecology. Oct. 1993;169(4):965-9. [pmid: 8238158].
Pearson GD, Veille JC, Rahimtoola S, et al. Peripartum cardiomyopathy: National Heart, Lung, and Blood Institute and Office of Rare Diseases (National Institutes of Health) workshop recommendations and review. JAMA. Mar. 1. 2000;283(9):1183-8. [pmid: 10703781].
Penning S, Garite TJ. Management of fetal distress. Obstetrics and Gynecology Clinics of North America. 1999;26(2):259-74. [pmid: 10399760].
Petersen R, Carter LS, Chescheir NC, et al. Effects of terbutaline sulfate on fetal cardiac function. Am J Obstet Gynecol. Sep. 1989;161(3):509-12. [pmid: 2782330].
Pisani RJ, Rosenow EC III. Pulmonary edema associated with tocolytic therapy. Ann Intern Med. May. 1. 1989;110(9):714-8. [pmid: 2648928].
Price AH, Clissold SP. Salbutamol in the 1980s. A reappraisal of its clinical efficacy. Drugs. 1989;38(1):77-122. [pmid: 2670512].
Quinn PG, Sherman BW, Tavill AS, et al. Terbutaline hepatitis in pregnancy: report of two cases and literature review. Am J Gastroenterol. May. 1994;89(5):781-4. [pmid: 8172156].
Quirk J, Bowes J. Intrapartum monitoring and management of the low birth weight fetus. Clinics in Perinatology. 1982;9(2):363-80. [pmid: 6749377].
Rasmussen OB, Larsen B. [Pulmonary edema during terbutaline infusion against threatened premature labor]. [Danish]. Ugeskrift for Laeger. Apr. 26. 1993;155(17):1303-4. [pmid: 8506581].
Rath W. Maintenance tocolysis between clinical practice and evidence-based medicine. [German]. Geburtshilfe und Frauenheilkunde. 2007;67(1):28-32.
Rath W, Bartz C. Tocolysis in preterm labor -Current status. [German]. Geburtshilfe und Frauenheilkunde. 2005;65(6):570-9.
Reichmann JP. Home uterine activity monitoring: the role of medical evidence. Obstet Gynecol. Aug. 2008;112(2 Pt 1):325-7. [pmid: 18669730].
Reichmann JP. Home uterine activity monitoring: an evidence review of its utility in multiple gestations. J Reprod Med. Sep. 2009;54(9):559-62. [pmid: 19947033].
Reid DL, Davidson SR, Phernetton TM, et al. Influence of terbutaline on ovine uterine response to prostaglandin E<sub>2</sub> challenge. American Journal of Obstetrics and Gynecology. 1992;166(1 I):231-5. [pmid: 1733200].
Rezapour M, Roomans GM, Backstrom T, et al. X-ray microanalysis of myometrium in parturient women at term. Journal of Submicroscopic Cytology & Pathology. Jan. 1996;28(1):75-80. [pmid: 8929628].
Ricci JM, Hariharan S, Helfgott A, et al. Oral tocolysis with magnesium chloride: a randomized controlled prospective clinical trial. Am J Obstet Gynecol. Sep. 1991;165(3):603-10. [pmid: 1892185].
Richards SR, Chang FE, Stempel LE. Hyperlactacidemia associated with acute ritodrine infusion. American Journal of Obstetrics and Gynecology. 1983;146(1):1-5. [pmid: 6846409].
Ridgway LE III, Muise K, Wright JW, et al. A prospective randomized comparison of oral terbutaline and magnesium oxide for the maintenance of tocolysis. American Journal of Obstetrics and Gynecology. 1990;163(3):879-82. [pmid: 2206076].
Rosene KA, Featherstone HJ, Benedetti TJ. Cerebral ischemia associated with parenteral terbutaline use in pregnant migraine patients. American Journal of Obstetrics & Gynecology. Jun. 15. 1982;143(4):405-7. [pmid: 7091205].
Ross MG, Nicolls E, Stubblefield PG, et al. Intravenous terbutaline and simultaneous beta 1-blockade for advanced premature labor. American Journal of Obstetrics & Gynecology. Dec. 15. 1983;147(8):897-902. [pmid: 6359887].
Rouse DJ, Widness JA, Weiner CP. Effect of intravenous beta-sympathomimetic tocolysis on human fetal serum erythropoietin levels. American Journal of Obstetrics and Gynecology. 1993;168(4):1278-82. [pmid: 8475975].
Russo LR, Besinger RE, Tomich PG, et al. Effect of chronic tocolytic therapy on maternal ventricular function in pregnant rabbits. American Journal of Obstetrics & Gynecology. Oct. 1996;175(4 Pt 1):847-52. [pmid: 8885734].
Rust OA, Bofill JA, Arriola RM, et al. The clinical efficacy of oral tocolytic therapy. [see comment]. American Journal of Obstetrics & Gynecology. Oct. 1996;175(4 Pt 1):838-42. [pmid: 8885732].
Ryden G. The effect of salbutamol and terbutaline in the management of premature labor. Acta Obstetricia et Gynecologica Scandinavica. 1977;56(4):293-6. [pmid: 602695].
Ryden G, Andersson RG, Berg G. Is the relaxing effect of beta-adrenergic agonists on the human myometrium only transitory?. Acta Obstet Gynecol Scand Suppl. 1982;108:47-51. [pmid: 6289597].
Sanchez-Ramos L, Huddleston JF. The therapeutic value of maintenance tocolysis: An overview of the evidence. Clinics in Perinatology. 2003;30(4):841-54. [pmid: 14714925].
Sanchez-Ramos L, Kaunitz AM, Gaudier FL, et al. Efficacy of maintenance therapy after acute tocolysis: a meta-analysis. [see comment]. American Journal of Obstetrics & Gynecology. Aug. 1999;181(2):484-90. [pmid: 10454704].
Santi MD, Henry GW, Douglas GL. Magnesium sulfate treatment of preterm labor as a cause of abnormal neonatal bone mineralization. Journal of Pediatric Orthopaedics. 1994;14(2):249-53. [pmid: 8188843].
Savvidou M, Edwards G, Davies N. Use of steroids, tocolytics and antibiotics in the management of preterm labor in Wales. J Obstet Gynaecol. Jul. 1998;18(4):315-7. [pmid: 15512098].
Sawaya GF, Robertson PA. Hepatotoxicity with the administration of nifedipine for treatment of preterm labor. American Journal of Obstetrics & Gynecology. Aug. 1992;167(2):512-3. [pmid: 1497061].
Scheerer LJ, Newman RB, Katz M. Tocodynamometry: Past and present. Current Problems in Obstetrics, Gynecology and Fertility. 1988;11(3):79-103.
Schwarz R, Retzke U. Cardiovascular effects of terbutalin in pregnant women. Acta Obstetricia et Gynecologica Scandinavica. 1983;62(5):419-23. [pmid: 6666555].
Sciscione AC, Ivester T, Largoza M, et al. Acute pulmonary edema in pregnancy. Obstetrics & Gynecology. Mar. 2003;101(3):511-5. [pmid: 12636955].
Shinkai N, Takasuna K, Takayama S. Inhibitory effects of formoterol on lipopolysaccharide-induced premature delivery through modulation of proinflammatory cytokine production in mice. Reproduction. 2003;125(2):199-203. [pmid: 12578533].
Shumway JB, Al-Malt A, Amon E, et al. Impact of oligohydramnios on maternal and perinatal outcomes of spontaneous premature rupture of the membranes at 18-28 weeks. Journal of Maternal -Fetal Medicine. 1999;8(1):20-3. [pmid: 10052841].
Sisson MC. Preventing preterm labor. Is terbutaline our best option?. [Review] [35 refs]. AWHONN Lifelines. Apr. 1997;1(2):42-6. [pmid: 9208748].
Skjaerris J, Aberg A. Prevention of prematurity in twin pregnancy by orally administered terbutaline. Acta Obstetricia et Gynecologica Scandinavica - Supplement. 1982;108:39-40. 1982.:39-40. [pmid: 6957127].
Slotkin TA, Baker FE, Dobbins SS, et al. Prenatal terbutaline exposure in the rat: Selective effects on development of noradrenergic projections to cerebellum. Brain Research Bulletin. 1989;23(4-5):263-5. [pmid: 2590837].
Slotkin TA, Kudlacz EM, Lappi SE, et al. Fetal terbutaline exposure causes selective postnatal increases in cerebellar alpha-adrenergic receptor binding. Life Sciences. 1990;47(22):2051-7. [pmid: 2177130].
Slotkin TA, Seidler FJ. Transient postnatal elevation of norepinephrine content and turnover in brain regions of rats exposed to terbutaline prenatally: evidence for autoregulation of noradrenergic development?. Research Communications in Chemical Pathology & Pharmacology. Jun. 1992;76(3):269-78. [pmid: 1636051].
Smigaj D, Roman-Drago NM, Amini SB, et al. The effect of oral terbutaline on maternal glucose metabolism and energy expenditure in pregnancy. American Journal of Obstetrics & Gynecology. May. 1998;178(5):1041-7. [pmid: 9609581].
Smith CS, Woodland MB. Clinical comparison of oral nifedipine and subcutaneous terbutaline for initial tocolysis. American Journal of Perinatology. Jul. 1993;10(4):280-4. [pmid: 8397562].
Smith GN, Brien JF. Use of nitroglycerin for uterine relaxation. Obstetrical and Gynecological Survey. 1998;53(9):559-65. [pmid: 9751938].
Souney PF, Kaul AF, Osathanondh R. Pharmacotherapy of preterm labor. [Review] [201 refs]. Clinical Pharmacy. Jan. 1983;2(1):29-44. [pmid: 6136361].
Spinillo A, Capuzzo E, Stronati M, et al. Obstetric risk factors for periventricular leukomalacia among preterm infants. Br J Obstet Gynaecol. Aug. 1998;105(8):865-71. [pmid: 9746379].
Stanton RJ. Comanagement of the patient on subcutaneous terbutaline pump therapy. Journal of Nurse-Midwifery. May. 1991;36(3):204-8. [pmid: 1856767].
Sullivan CA, Morrison JC. Emergent management of the patient in preterm labor. Obstetrics and Gynecology Clinics of North America. 1995;22(2):197-214. [pmid: 7651666].
Svenningsen NW. Follow-up studies on preterm infants after maternal beta-receptor agonist treatment. Acta Obstet Gynecol Scand Suppl. 1982;108:67-70. [pmid: 6957129].
TambyRaja RL. Current concepts in the management of preterm labor. Singapore Med J. Dec. 1989;30(6):578-83. [pmid: 2699676].
Tan PC, Daud SA, Omar SZ. Concurrent dinoprostone and oxytocin for labor induction in term premature rupture of membranes: A randomized controlled trial. Obstetrics and Gynecology. 2009;113(5):1059-65. [pmid: 19384121].
Teoh TG. Outcome of 80 cases of external cephalic version. Medical Journal of Malaysia. Dec. 1996;51(4):469-74. [pmid: 10968036].
Thornton JG. Maintenance tocolysis. BJOG. Mar. 1. 2005;112:118-21. [pmid: 15715609].
Thorp J, Hartmann KE. Evidence-based management of preterm labor: The role of tocolytics and antibiotics. Current Problems in Obstetrics, Gynecology and Fertility. 2002;25(6):212-29.
Thoulon JM, Berland M, Beaune J. Beta-sympathomimetics and premature delivery. [French]. Revue Francaise de Gynecologie et d'Obstetrique. 1985;80(12):901-15.
Thurlow JA, Kinsella SM. Intrauterine resuscitation: Active management of fetal distress. International Journal of Obstetric Anesthesia. 2002;11(2):105-16. [pmid: 15321562].
Tibaldi JM, Lorber DL, Nerenberg A. Diabetic ketoacidosis and insulin resistance with subcutaneous terbutaline infusion: a case report. American Journal of Obstetrics & Gynecology. Aug. 1990;163(2):509-10. [pmid: 2117390].
Travis BE, McCullough JM. Pharmacotherapy of preterm labor. Pharmacotherapy. Jan. 1993;13(1):28-36. [pmid: 8437965].
Tsatsaris V, Papatsonis D, Goffinet F, et al. Tocolysis with nifedipine or beta-adrenergic agonists: a meta-analysis. Obstet Gynecol. May. 2001;97(5 Pt 2):840-7. [pmid: 11336775].
US National Heart,Lung,and Blood Institute.National Asthma Education Program. Executive summary: management of asthma during pregnancy, Report of the Working Group on Asthma and Pregnancy. United States Department of Health and Human Services National Institutes of Health. 1993.
Van de BM, Van BF, Lineman R, et al. Perinatal factors and periventricular-intraventricular hemorrhage in preterm infants. Am J Dis Child. Nov. 1986;140(11):1125-30. [pmid: 3532762].
Varnagy A, Tamas P, Toth T, et al. Comparison of atosiban-magnesium sulfate combination and terbutalin for tocolysis (Preliminary study). [Hungarian]. Magyar Noorvosok Lapja. 2003;66(6):331-4.
Veille JC. Management of preterm premature rupture of membranes. [Review] [61 refs]. Clinics in Perinatology. Dec. 1988;15(4):851-62. [pmid: 3061702].
Viamontes CM. Pharmacologic intervention in the management of preterm labor: an update. J Perinat Neonatal Nurs. Mar. 1996;9(4):13-30. [pmid: 8699364].
Von Der Pool BA. Preterm labor: Diagnosis and treatment. American Family Physician. 1998;57(10):2457-64. [pmid: 9614414].
Wager J, Fredholm BB, Lunell NO, et al. Development of tolerance to oral salbutamol in the third trimester of pregnancy: A study of circulatory and metabolic effects. British Journal of Clinical Pharmacology. 1981;12(4):489-95. [pmid: 6271156].
Weale NK, Kinsella SM. Intrauterine fetal resuscitation. Anaesthesia and Intensive Care Medicine. 2007;8(7):282-5.
Weidinger H, Wiest W, Schleich A, et al. The effects of betamimetic drugs used for tocolysis on the fetal myocardium. J Perinat Med. 1976;4(4):280-5. [pmid: 1011065].
Weintraub Z, Solovechick M, Reichman B, et al. Effect of maternal tocolysis on the incidence of severe periventricular/intraventricular haemorrhage in very low birthweight infants. Arch Dis Child Fetal Neonatal Ed. Jul. 2001;85(1):F13-F17. [pmid: 11420315].
Wheeler DG. Preterm birth prevention. J Nurse Midwifery. Mar. 1994;39(2 Suppl):66S-80S. [pmid: 8035246].
Multicenter randomized, controlled trial of a preterm birth prevention program. Collaborative Group on Preterm Birth Prevention. Am J Obstet Gynecol. Aug. 1993;169(2 Pt 1):352-66. [pmid: 8362947].
Preterm labor. International Journal of Gynecology and Obstetrics. 1995;50(3):303-13. [pmid: 8543120].
Effectiveness and safety of the oxytocin antagonist atosiban versus beta-adrenergic agonists in the treatment of preterm labor. The Worldwide Atosiban versus Beta-agonists Study Group. BJOG. Feb. 2001;108(2):133-42. [pmid: 11236112].
Abstracts of papers and posters to be presented at the ACOG 53rd Annual Clinical Meeting. May 7-11, 2005. San Francisco, California. Obstetrics & Gynecology. Apr. 2005;105(4):1s-124s.

## Full-Text: SQ terbutaline pump was not given as maintenance tocoytic therapy in at least one group (n=61)

Adam K, Ou CN, Cotton DB. Combined effect of terbutaline and betamethasone on glucose homeostasis in preterm labor. Fetal Diagnosis and Therapy. 1993;8(3):187-94. [pmid: 8240692].
Barden TP, Stander RW. Myometrial and cardiovascular effects of an adrenergic blocking drug in human pregnancy. Am J Obstet Gynecol. May. 1. 1968;101(1):91-9. [pmid: 5645637].
Beall MH, Edgar BW, Paul RH, et al. A comparison of ritodrine, terbutaline, and magnesium sulfate for the suppression of preterm labor. Am J Obstet Gynecol. Dec. 15. 1985;153(8):854-9. [pmid: 4073155].
Berg G, Lindberg C, Ryden G. Terbutaline in the treatment of preterm labor. European Journal of Respiratory Diseases - Supplement. 1984;134:219-30. 1984.:219-30. [pmid: 6586483].
Bergman B, Hedner T. Antepartum administration of terbutaline and the incidence of hyaline membrane disease in preterm infants. Acta Obstet Gynecol Scand. 1978;57(3):217-21. [pmid: 665163].
Bishop EH, Woutersz TB. Arrest of premature labor. JAMA. Nov. 25. 1961;178:812-4. [pmid: 13869494].
Bivins HA, Newman RB, Fyfe DA, et al. Randomized comparative trial of indomethacin and terbutaline for the long term treatment of preterm labor. American Journal of Obstetrics and Gynecology. 1993;168:375.
Bohm N, Adler CP. Focal necroses, fatty degeneration and subendocardial nuclear polyploidization of the myocardium in newborns after beta-sympathicomimetic suppression of premature labor. Eur J Pediatr. May. 1981;136(2):149-57. [pmid: 6112148].
Bremme K, Eneroth P. Serum estriol levels during beta-receptor agonist infusion in the third trimester of pregnancy. Gynecologic & Obstetric Investigation. 1981;12(2):93-8. [pmid: 6114905].
Bremme K, Eneroth P, Hagenfeld L, et al. Changes in maternal serum aldosterone, potassium and prolactin levels during beta-receptor agonist treatment in third trimester pregnancies. Hormone & Metabolic Research. Apr. 1982;14(4):198-204. [pmid: 6282724].
Caritis SN, Carson D, Greebon D, et al. A comparison of terbutaline and ethanol in the treatment of preterm labor. American Journal of Obstetrics and Gynecology. 1982;142(2):183-90. [pmid: 7055183].
Chan J, Cabrol D, Ingemarsson I, et al. Pragmatic comparison of beta2-agonist side effects within the Worldwide Atosiban versus Beta Agonists study. Eur J Obstet Gynecol Reprod Biol. Sep. 2006;128(1-2):135-41. [pmid: 16504369].
Chau AC, Gabert HA, Miller JM Jr. A prospective comparison of terbutaline and magnesium for tocolysis. Obstetrics & Gynecology. Nov. 1992;80(5):847-51. [pmid: 1407926].
Coleman B, Grant T, Mueller B. Hospitalization and infant outcomes among women exposed and unexposed to tocolysis. J Perinatol. Apr. 2005;25(4):258-64. [pmid: 15616611].
Cotton DB, Strassner HT, Lipson LG, et al. The effects of terbutaline on acid base, serum electrolytes, and glucose homeostasis during the management of preterm labor. American Journal of Obstetrics & Gynecology. Nov. 15. 1981;141(6):617-24. [pmid: 7315890].
Dolfin T, Skidmore MB, Fong KW, et al. Perinatal factors that influence the incidence of subependymal and intraventricular hemorrhage in low birthweight infants. Am J Perinatol. Jan. 1984;1(2):107-13. [pmid: 6518059].
Dudley D, Gagnon D, Varner M. Long-term tocolysis with intravenous magnesium sulfate. Obstetrics and Gynecology. 1989;73(3 I):373-8. [pmid: 2915861].
Fisher JE, Smith RS, Lagrandeur R, et al. Gestational diabetes mellitus in women receiving beta-adrenergics and corticosteroids for threatened preterm delivery. Obstet Gynecol. Dec. 1997;90(6):880-3. [pmid: 9397094].
Fredholm BB, Lunell NO, Persson B, et al. Development of tolerance to the metabolic actions of beta 2-adrenoceptor stimulating drugs. Acta Obstet Gynecol Scand Suppl. 1982;108:53-9. [pmid: 6289598].
Haspedis L. Terbutaline in the treatment of preterm labor: a comparison of intravenous and subcutaneous administration. Journal of the American Osteopathic Association. Apr. 1988;88(4):489-93. [pmid: 3366670].
Herron MA, Katz M, Creasy RK. Evaluation of a preterm birth prevention program: preliminary report. Obstetrics & Gynecology. Apr. 1982;59(4):452-6. [pmid: 7078897].
Howard J, Killam AP, Penney LL, et al. A double blind randomized study of terbutaline in premature labor. Military Medicine. 1982;147(4):305-7. [pmid: 6815559].
Ingemarsson I. Effect of terbutaline on premature labor. A double-blind placebo-controlled study. American Journal of Obstetrics & Gynecology. Jun. 15. 1976;125(4):520-4. [pmid: 790961].
Ingemarsson I, Bengtsson B. A five-year experience with terbutaline for preterm labor: low rate of severe side effects. Obstetrics & Gynecology. Aug. 1985;66(2):176-80. [pmid: 4022480].
Jimenez Aramayo JF, Jimenez MF, Lopez RC. [Tocolytic therapy with magnesium sulfate and terbutaline for inhibition of premature labor]. Ginecol Obstet Mex. Sep. 1990;58:265-9. [pmid: 2276652].
Karlsson K, Krantz M, Hamberger L. Comparison of various betamimetics on preterm labor, survival and development of the child. Journal of Perinatal Medicine. 1980;8(1):19-26. [pmid: 7365667].
Katz M, Robertson PA, Creasy RK. Cardiovascular complications associated with terbutaline treatment for preterm labor. Am J Obstet Gynecol. Mar. 1. 1981;139(5):605-8. [pmid: 7468724].
Kilburn KH, Thrasher J, Immers NB. Autism, terbutaline and neurological impairment, CR Online Journal. http://www.collegiumramazzini.org/gest/up/Kilb urn.pdf. 29-4-2010.
Korenbrot CC, Aalto LH, Laros RK Jr. The cost effectiveness of stopping preterm labor with beta-adrenergic treatment. N Engl J Med. Mar. 15. 1984;310(11):691-6. [pmid: 6142417].
Kosasa TS, Nakayama RT, Hale RW, et al. Ritodrine and terbutaline compared for the treatment of preterm labor. Acta Obstet Gynecol Scand. 1985;64(5):421-6. [pmid: 3904315].
Kovacs L, Zalanyi S Jr, Szasz K, et al. [Use of terbutaline sulfate (Bricalyn Astra-Egyt) for betamimetic tocolysis]. Zentralbl Gynakol. 1982;104(22):1445-50. [pmid: 6891878].
Kuno N, Ishikawa K. Serum creatine phosphokinase elevation in patients treated with intravenous magnesium sulfate. International Journal of Gynecology and Obstetrics. 2002;76(3):257-66. [pmid: 11880128].
Lampert MB, Hibbard J, Weinert L, et al. Peripartum heart failure associated with prolonged tocolytic therapy. Am J Obstet Gynecol. Feb. 1993;168(2):493-5. [pmid: 8438916].
Laohapojanart N, Soorapan S, Wacharaprechanont T, et al. Safety and efficacy of oral nifedipine versus terbutaline injection in preterm labor. Journal of the Medical Association of Thailand. Nov. 2007;90(11):2461-9. [pmid: 18181335].
Laros RK Jr, Kitterman JA, Heilbron DC, et al. Outcome of very-low-birth-weight infants exposed to beta-sympathomimetics in utero. Am J Obstet Gynecol. Jun. 1991;164(6 Pt 1):1657-64. [pmid: 2048614].
Mawaldi L, Duminy P, Tamim H. Terbutaline versus nifedipine for prolongation of pregnancy in patients with preterm labor. International Journal of Gynaecology & Obstetrics. Jan. 2008;100(1):65-8. [pmid: 17894937].
Miller JM Jr, Keane MW, Horger EO III. A comparison of magnesium sulfate and terbutaline for the arrest of premature labor. A preliminary report. J Reprod Med. Jun. 1982;27(6):348-51. [pmid: 7120214].
Mosler KH, Dornhöfer W. The inhibition of premature labor by -adrenergic sympathomimetics and prostaglandin antagonists in managing premature onset of labor. Naunyn Schmiedebergs Arch Pharmacol. 1973;277.
Phuapradit W, Pongthai S, Chaturachinda K. Treatment of premature labor with terbutaline. J Med Assoc Thai. Aug. 1983;66(8):453-7. [pmid: 6685750].
Pitzer M, Schmidt MH, Esser G, et al. Child development after maternal tocolysis with beta-sympathomimetic drugs. Child Psychiatry Hum Dev. 2001;31(3):165-82. [pmid: 11196009].
Pranikoff J, Helmchen R, Evertson L. Tocolytic therapy and intraventricular hemorrhage in the neonate. Am J Obstet Gynecol. 1991;164:387.
Robertson PA, Herron M, Katz M, et al. Maternal morbidity associated with isoxsuprine and terbutaline tocolysis. Eur J Obstet Gynecol Reprod Biol. May. 1981;11(6):371-8. [pmid: 7195835].
Ron-El R, Mor Z, Weinraub Z, et al. Triplet, quadruplet and quintuplet pregnancies. Management and outcome. Acta Obstet Gynecol Scand. Jul. 1992;71(5):347-50. [pmid: 1326209].
Sciscione A, Gorman R, Schlossman P, et al. A randomized prospective study of intravenous magnesium sulfate, ritrodine, and subcutaneous terbutaline as treatments for preterm labor. American Journal of Obstetrics and Gynecology. 1993;168:376.
Sciscione AC, Stamilio DM, Manley JS, et al. Tocolysis of preterm contractions does not improve preterm delivery rate or perinatal outcomes. Am J Perinatol. Mar. 1998;15(3):177-81. [pmid: 9572373].
Sharif DS, Huhta JC, Moise KJ Jr, et al. Changes in fetal hemodynamics with terbutaline treatment and premature labor. J Clin Ultrasound. Feb. 1990;18(2):85-9. [pmid: 2156911].
Smythe AR, Sakakini J Jr. Maternal metabolic alterations secondary to terbutaline therapy for premature labor. Obstetrics & Gynecology. May. 1981;57(5):566-70. [pmid: 7219905].
Solum T. Clinical experience of terbutaline in preterm labor. Acta Obstetricia et Gynecologica Scandinavica. 1982;61(Suppl. 108):37-8.
Sorensen KE, Borlum KG. Fetal cardiac function in response to long-term maternal terbutalin treatment. Acta Obstetricia et Gynecologica Scandinavica. 1988;67(2):105-7. [pmid: 3176921].
Spatling L, Fallenstein F, Schneider H, et al. Bolus tocolysis: treatment of preterm labor with pulsatile administration of a beta-adrenergic agonist. Am J Obstet Gynecol. Mar. 1989;160(3):713-7. [pmid: 2564741].
Stubblefield PG, Heyl PS. Treatment of premature labor with subcutaneous terbutaline. Obstetrics & Gynecology. Apr. 1982;59(4):457-62. [pmid: 7078898].
Surichamorn P. The efficacy of terbutaline and magnesium sulfate in the management of preterm labor. J Med Assoc Thai. Jan. 2001;84(1):98-104. [pmid: 11281506].
Svenningsen NW, Holmquist P, Ingemarsson I. Antenatal management of terbutaline--effects on infants born preterm. J Singapore Paediatr Soc. 1985;27(3-4):208-14. [pmid: 3831605].
Takagi K, Satoh K. Is long-term tocolysis effective for threatened premature labor?. Journal of International Medical Research. 2009;37(1):227-39. [pmid: 19215695].
Thorp JA, Jones PG, Clark RH, et al. Perinatal factors associated with severe intracranial hemorrhage. Am J Obstet Gynecol. Oct. 2001;185(4):859-62. [pmid: 11641666].
Wagner JM, Morton MJ, Johnson KA, et al. Terbutaline and maternal cardiac function. JAMA. Dec. 11. 1981;246(23):2697-701. [pmid: 7310963].
Wallace RL, Caldwell DL, Ansbacher R, et al. Inhibition of premature labor by terbutaline. Obstetrics & Gynecology. Apr. 1978;51(4):387-92. [pmid: 662220].
Weerakul W, Chittacharoen A, Suthutvoravut S. Nifedipine versus terbutaline in management of preterm labor. Int J Gynaecol Obstet. Mar. 2002;76(3):311-3. [pmid: 11880137].
Weiss MA. Retrospective analysis of the effects of ritodrine and terbutaline in the management of preterm labor. Clin Pharm. Sep. 1982;1(5):453-6. [pmid: 7184677].
Wright JW, Patterson RM, Ridgway LE III, et al. Effect of tocolytic agents on fetal umbilical velocimetry. American Journal of Obstetrics & Gynecology. Sep. 1990;163(3):748-50. [pmid: 2206066].
Zalut T, Reed KL, Shenker L. Incidence of premature labor in diabetic patients. American Journal of Perinatology. 1985;2(4):276-8. [pmid: 4052177].

## Full-Text: Review article, letter to the editor commentary, or newspaper article (n=51)

Benedetti TJ. Maternal complications of parenteral beta-sympathomimetic therapy for premature labor. Am J Obstet Gynecol. Jan. 1. 1983;145(1):1-6. [pmid: 6849333].
Bey M, Blanchard AC, Darnell J, et al. Myocardial necrosis in a newborn after long-term maternal subcutaneous terbutaline for suppression of premature labor. [comment]. American Journal of Obstetrics & Gynecology. Jul. 1992;167(1):292-3. [pmid: 1442944].
Boyle JG. Beta-adrenergic agonists. Clinical Obstetrics and Gynecology. 1995;38(4):688-96. [pmid: 8616966].
Brinsmead M. Fetal and neonatal effects of drugs administered in labor. Med J Aust. May. 4. 1987;146(9):481-6. [pmid: 2886897].
Catanzarite V. Subcutaneous tocolytic infusion therapy for patients at very high risk for preterm birth. [comment]. Journal of Perinatology. Dec. 1992;12(4):387-8. [pmid: 1479468].
Challis JRG, Lye FAPS. Control of parturition. Labor and Delivery: The Proceedings of the 2nd World Congress on Labor and Delivery. May 1997. Rome, Italy. Taylor & Francis. 1998:9.
Clayton J, Senior J, Marshall K. Drugs for preterm labor. Practitioner. Jul. 1993;237(1528):582-4. [pmid: 8415391].
Cole RM, Lamont RF. Current perspectives on drug treatment for preterm labor. J Obstet Gynaecol. Jul. 1998;18(4):309-14. [pmid: 15512097].
Creasy RK. Side effects of beta-mimetic administration: Tocolytic agents. Proceedings of a Symposium on Tocolytic Therapy. New Orleans. The Society of Perinatal Obstetricians. 1980:87.
Crowther CA, Moore V. Magnesium maintenance therapy for preventing preterm birth after threatened preterm labor. Cochrane Database of Systematic Reviews. Mar. 1998;(1).
Cseh I. Place and role of Bricanyl in obstetrical practice. Therapia Hungarica. 1993;41(1):23-7.
Devoe LD. Terbutaline pump treatment of premature labor. [comment]. Southern Medical Journal. Sep. 1993;86(9):1076. 1993. [pmid: 8240536].
Drife J, Kuenzel W. Editorial. European Journal of Obstetrics Gynecology and Reproductive Biology. 2006;128(1-2):1-4.
Gill P, Smith M, McGregor C. Terbutaline by pump to prevent recurrent preterm labor. MCN, American Journal of Maternal Child Nursing. May. 1989;14(3):163-7.
Gookin KS, Nagey DA, Bailey-Jones C, et al. Randomized comparison of home uterine activity monitoring and routine care in patients discharged after treatment for preterm labor. [2]. Obstetrics and Gynecology. 1994;83(1):159-60. [pmid: 8272300].
Hannah ME. Search for best tocolytic for preterm labor. Lancet. Aug. 26. 2000;356(9231):699-700. [pmid: 11085687].
Hawkins D. Management of premature labor. Journal of Obstetrics & Gynaecology. 1989;10(Suppl. 1):S10-S12.
HAYES, Inc. Continuous subcutaneous terbutaline infusion for treatment of preterm labor. Structured abstract. Lansdale, Pa. Hayes, Inc. 2006.
Hearne AE, Nagey DA. Therapeutic agents in preterm labor: tocolytic agents. Clin Obstet Gynecol. Dec. 2000;43(4):787-801. [pmid: 11100296].
Huddleston JF. Preterm labor. Clin Obstet Gynecol. Mar. 1982;25(1):123-36. [pmid: 6121640].
Janke J. Use of terbutaline sulfate in a subcutaneous infusion. Pump to treat preterm labor. Nurse Practitioner. 1993;18(9):33-4. [pmid: 8414232].
Jelsema RD. Subcutaneous terbutaline pump. [comment]. Journal of Reproductive Medicine. Apr. 1998;43(4):401-2. [pmid: 9583076].
Katz VL, Seeds JW. Fetal and neonatal cardiovascular complications from beta-sympathomimetic therapy for tocolysis. Am J Obstet Gynecol. Jul. 1989;161(1):1-4. [pmid: 2750790].
Lam F, Gill P. Subcutaneous terbutaline therapy in triplet gestation. Keith L, Blickstein I, editors. Triplet pregnancies and their consequences. New York. Parthenon. 2002:181-202.
Lam F. Miniature pump infusion of terbutaline: An option in preterm labor. Contemporary OB/GYN. 1988;33:53-70.
Lam F. The dosing of subcutaneous terbutaline pump tocolytic therapy is critical. [comment]. American Journal of Obstetrics & Gynecology. Oct. 1992;167(4 Pt 1):1156-7. [pmid: 1415415].
Landesman R, Fuchs F. Control of uterine activity and prevention of premature birth. Basic Life Sci. 1974;4(PT. B):219-41. [pmid: 4156643].
Lashgari S, Kueck AS, Oyelese Y. Atrial fibrillation in pregnancy associated with oral terbutaline therapy. [comment]. Obstetrics & Gynecology. Apr. 2003;101(4):814. 2003. [pmid: 12681894].
Leveno KJ, Cunningham FG. Beta-adrenergic agonists for preterm labor. N Engl J Med. Jul. 30. 1992;327(5):349-51. [pmid: 1352375].
Lipshitz J. Preterm parturition. Beta-adrenergic agonists. Semin Perinatol. Jul. 1981;5(3):252-65. [pmid: 6116282].
Martin AJ. Severe unwanted effects associated with betasympathomimetics when used in the treatment of premature labor: causes, incidence and preventative measures. Br J Clin Pract. Sep. 1981;35(9):325-9. [pmid: 6120000].
McPherson ML. Management of preterm labor with continuous subcutaneous home terbutaline therapy. Journal of Home Health Care Practice. Nov. 1992;5(1):22-5.
Miller DD. Tocolytic therapy for the prevention of preterm labor. Journal of Intravenous Nursing. 1995;18(5):233-8.
Moise KJ Jr. Terbutaline pump treatment of premature labor. [comment]. Southern Medical Journal. Sep. 1993;86(9):1076-7. [pmid: 8367762].
Monga M, Creasy RK. Pharmacologic management of preterm labor. Semin Perinatol. Feb. 1995;19(1):84-96. [pmid: 7754414].
Moore B, Briggs G, Freeman R. Terbutaline for tocolysis: Do advantages outweigh risks?. Contemp OB/GYN. 1988;32:53.
Nanda K, Cook LA, Gallo MF, et al. Terbutaline pump maintenance therapy after threatened preterm labor for preventing preterm birth. Cochrane Database of Systematic Reviews. Dec. 2002;(4).
Niebyl JR, Johnson JW. Inhibition of preterm labor. Clin Obstet Gynecol. Mar. 1980;23(1):115-26. [pmid: 6102498].
Nightingle SL. From the Food and Drug Administration. Journal of the American Medical Association. 1998;279(1):9. [pmid: 9424027].
Norwitz ER, Robinson JN, Challis JRG. The control of labor. New England Journal of Medicine. 1999;341(9):660-6. [pmid: 10460818].
Prevost RR. Treatment of pregnancy-related illnesses. American Pharmacy. 1995;35(10):25-32. [pmid: 8533708].
Roan S. T-pump therapy undergoing a close second look. Los Angeles Times -- Southern California Edition. Front Page. Sep. 15. 1998:S3.
Rogge P, Young S, Goodlin R. Post-partum pulmonary oedema associated with preventive therapy for premature labor. Lancet. May. 12. 1979;313(8124):1026-7. [pmid: 86736].
Rose VL. Warning on terbutaline sulfate in preterm labor. American Family Physician. 1998;57(8):2014-5.
Shellhaas CS, Iams JD. Ambulatory management of preterm labor. Clinical Obstetrics and Gynecology. 1998;41(3):491-502. [pmid: 9742347].
Simhan HN, Caritis SN. Prevention of preterm delivery. N Engl J Med. Aug. 2. 2007;357(5):477-87. [pmid: 17671256].
Unbehaun V. Effects of sympathomimetic tocolytic agents on the fetus. J Perinat Med. 1974;2(1):17-29. [pmid: 4157074].
Voelker R. Infusion helps prolong pregnancy. Journal of the American Medical Association. 1998;279(12):902.
Witter FR, Zimmerman AW, Reichmann JP, et al. In utero beta 2 adrenergic agonist exposure and adverse neurophysiologic and behavioral outcomes. Am J Obstet Gynecol. Dec. 2009;201(6):553-9. [pmid: 19961985].
New help for preterm birth prevention: pump therapy lets patients remain at home. Naacog Newsletter. Oct. 1989;16(4):4. 10, 1989.
Worth noting: terbutaline pump warning. OBGYN Malpract Prev. Mar. 1997;4(3):23.

## Full-Text: A study of maternal/neonatal outcomes or harms without at least one comparison group (n=25)

Allbert JR, Wise CA, Lou CH, et al. Subcutaneous tocolytic infusion therapy for patients at very high risk for preterm birth. J Perinatol. Mar. 1992;12(1):28-31. [pmid: 1348530].
Ambrose S, Jacques D, Stanziano G. Clinical and economic outcomes associated with home vs hospital use of continuous subcutaneous tocolytic therapy. Proceedings of the annual meeting of the American College of Obstetricians and Gynecologists. 2001.
Ambrose S, Rhea DJ, Istwan NB, et al. Clinical and economic outcomes of preterm labor management: inpatient vs outpatient. Journal of Perinatology. Aug. 2004;24(8):515-9. [pmid: 15141268].
Elliott JP, Bergauer NK, Jacques DL, et al. Pregnancy prolongation in triplet pregnancies. Oral vs. continuous subcutaneous terbutaline.
Journal of Reproductive Medicine. Nov. 2001;46(11):975-82. [pmid: 11762154].
Elliott JP, Flynn MJ, Kaemmerer EL, et al. Terbutaline pump tocolysis in high-order multiple gestation. [see comment]. Journal of Reproductive Medicine. Nov. 1997;42(11):687-94. [pmid: 9408866].
Elliott JP, Istwan NB, Rhea D, et al. The occurrence of adverse events in women receiving continuous subcutaneous terbutaline therapy. American Journal of Obstetrics & Gynecology. Oct. 2004;191(4):1277-82. [pmid: 15507953].
Elliott JP, Radin TG. Quadruplet pregnancy: contemporary management and outcome. [see comment]. Obstetrics & Gynecology. Sep. 1992;80(3 Pt 1):421-4. [pmid: 1495698].
Fischer JR, Kaatz BL. Continuous subcutaneous infusion of terbutaline for suppression of preterm labor. Clinical Pharmacy. Apr. 1991;10(4):292-6. [pmid: 2032446].
Gaziano E, Wagner W, Rhea D. Inpatient vs. outpatient surveillance for singleton pregnancies following inpatient treatment with magnesium sulfate for preterm labor. Society for Gynecologic Investigation Annual Meeting. 2004.
Gianopoulos J, Carlson N, Schumachen B. SQ terbutaline pump for premature labor. Am J Obstet Gynecol. 1991;164:426.
Hamersley SL, Coleman SK, Bergauer NK, et al. Delayed-interval delivery in twin pregnancies. J Reprod Med. Feb. 2002;47(2):125-30. [pmid: 11883351].
Hammersley S, Pinckert T, Gorman K. The use of continuous subcutaneous terbutaline in a private maternal–fetal medicine practice. Obstet Gynecol. 1999;93:67-8.
Jones J, Morrison J, Istwan N, et al. The interval to spontaneous delivery following discontinuation of maintenance tocolysis. Journal of Maternal -Fetal and Neonatal Medicine. 2006;19(6):331-5. [pmid: 16801308].
Jones P, Greenspan J, Bochner C. Continuous subcutaneous terbutaline infusion for the prevention of recurrent preterm labor. Am J Obstet Gynecol. 1991;164:426.
Lam F, Bergauer N, Stanziano G, et al. Pregnancy prolongation and route of tocolytic administration in patients with singleton gestation. Am J Obstet Gynecol. 1998;178(Suppl. 1):180. [pmid: 9465826].
Lam F, Bergauer NK, Coleman SK, et al. A comparison of gestational days gained with oral terbutaline versus continuous subcutaneous terbutaline in women with twin gestations. Journal of Perinatology. Oct. 2000;20(7):408-13. [pmid: 11076323].
Moise KJ Jr, Sala DJ, Zurawin RK, et al. Continuous subcutaneous terbutaline pump therapy for premature labor: safety and efficacy. Southern Medical Journal. Mar. 1992;85(3):255-60. [pmid: 1546349].
Perry KG Jr, Morrison JC, Rust OA, et al. Incidence of adverse cardiopulmonary effects with low-dose continuous terbutaline infusion. American Journal of Obstetrics & Gynecology. Oct. 1995;173(4):1273-7. [pmid: 7485336].
Pomini F, De CS, Ferrazzani S, et al. [Continuous subcutaneous administration of terbutaline in the therapy of threatening premature labor]. [Italian]. Minerva Ginecologica. Jan. 1993;45(1-2):57-63. [pmid: 8469366].
Rebarber A, Roman A, Istwan N. Factors associated with spontaneous preterm delivery in singleton gestations. Obstet Gynecol. 2004;103(4).
Rebarber A, Cleary-Goldman J, Istwan N, et al. The association of elective cessation of tocolysis and preterm birth in singleton gestations. American Journal of Perinatology. May. 2009;26(5):351-5. [pmid: 19067281].
Roman A, Rebarber A, Istwan N. Clinical and demographic factors associated with spontaneous preterm delivery in twin pregnancies diagnosed with preterm labor at 34 weeks. Am J Obstet Gynecol. 2003;189:S123.
Viscarello R, Griffith S, Jacques D. The effect of proactive dose acceleration in triplets receiving continuous subcutaneous tocolysis. Obstet Gynecol. 2002;99:12.
Weinbaum P, Olson M. The effect of subcutaneous infusion on uterine activity in patients at risk for preterm delivery. Am J Obstet Gynecol. 1993;166:362.
Wolfsen R, Winn S. Prolongation of twin pregnancy with magnesium sulphate / subcutaneous terbutaline pump therapy in the face of advanced cervical dilation and effacement. Am J Obstet Gynecol. 1992;166:366.

## Full-Text: Case reports (n=18):

Benedetti TJ, Hargrove JC, Rosene KA. Maternal pulmonary edema during premature labor inhibition. Obstet Gynecol. Jun. 1982;59(6 Suppl):33S-7S. [pmid: 7088424].
Brandstetter RD, Gotz V. Inadvertent overdose of parenteral terbutaline. Lancet. 1980;1(8166):485. [pmid: 6102210].
Clesham GJ. Beta adrenergic agonists and pulmonary oedema in preterm labor. BMJ. Jan. 22. 1994;308(6923):260-2. [pmid: 8111264].
Gimovsky ML. Short-term tocolysis adjunctive to intrapartum term breech management. American Journal of Obstetrics and Gynecology. 1985;153(2):233. [pmid: 4037019].
Gross TL, Sokol RJ. Severe hypokalemia and acidosis: a potential complication of beta-adrenergic treatment. Am J Obstet Gynecol. Dec. 15. 1980;138(8):1225-6. [pmid: 7446635].
Hawker F. Five cases of pulmonary oedema associated with beta 2-sympathomimetic treatment of premature labor. Anaesth Intensive Care. May. 1984;12(2):159-62. [pmid: 6476350].
Hill WC. Overdosage of subcutaneous terbutaline in the treatment of preterm labor. Nebraska Medical Journal. Jul. 1986;71(7):242-3. [pmid: 3736707].
Ingemarsson I. Tocolytic therapy and clinical experience. Combination therapy. BJOG : An International Journal of Obstetrics & Gynaecology. Mar. 1. 2005;112:89-93. 2005 Mar.:89-93. [pmid: 15715603].
Jacobs MM, Knight AB, Arias F. Maternal pulmonary edema resulting from betamimetic and glucocorticoid therapy. Obstet Gynecol. Jul. 1980;56(1):56-9. [pmid: 6104317].
Kalb KA. Women's experiences using terbutaline pump therapy for the management of preterm labor. University of Minnesota. 1993.
Levy DL. Morbidity caused by terbutaline infusion pump therapy. [comment]. American Journal of Obstetrics & Gynecology. Jun. 1994;170(6):1835. 1994. [pmid: 8203446].
Mabie WC, Pernoll ML, Witty JB, et al. Pulmonary edema induced by betamimetic drugs. South Med J. Nov. 1983;76(11):1354-60. [pmid: 6635722].
Mahon WA, Reid DW, Day RA. The in vivo effects of beta adrenergic stimulation and blockade on the human uterus at term. J Pharmacol Exp Ther. Apr. 1967;156(1):178-85. [pmid: 6023594].
Milos M, Aberle DR, Parkinson BT, et al. Maternal pulmonary edema complicating beta-adrenergic therapy of preterm labor. AJR Am J Roentgenol. Nov. 1988;151(5):917-8. [pmid: 3263022].
Sala DJ, Moise KJ Jr. The treatment of preterm labor using a portable subcutaneous terbutaline pump. JOGNN - Journal of Obstetric, Gynecologic, & Neonatal Nursing. Mar. 1990;19(2):108-15.
Semchyshyn S, Zuspan FP, O'Shaughnessy R. Pulmonary edema associated with the use of hydrocortisone and a tocolytic agent for the management of premature labor. J Reprod Med. Jan. 1983;28(1):47-52. [pmid: 6834348].
Thorkelsson T, Loughead JL. Long-term subcutaneous terbutaline tocolysis: report of possible neonatal toxicity. Journal of Perinatology. Sep. 1991;11(3):235-8. [pmid: 1919821].
Tye KH, Desser KB, Benchimol A. Angina pectoris associated with use of terbutaline for premature labor. JAMA. Aug. 15. 1980;244(7):692-3. [pmid: 7392171].

## Full-Text: Excluded for another reason (no patient data, clearly not relevant to SQ terbutaline pump, betamimetic treatment not specified) (n=13)

Caritis SN. Ritodrine infusion and cardiomyopathy (I). American Journal of Obstetrics and Gynecology. 1990;163(1 I):254-5. [pmid: 2248643].
Elliott J, Istwan N, Jacques. Expectant management of the quadruplet pregnancy: inpatient or outpatient. Am J Obstet Gynecol. 2001;185(6 Suppl. 1):110.
Eskes TK, de HJ. The influence of beta-mimetic catecholamines upon the fetal circulation. Z Geburtshilfe Perinatol. Apr. 1972;176(2):97-107. [pmid: 4403212].
Goldenberg RL, Rouse DJ. Prevention of premature birth. N Engl J Med. Jul. 30. 1998;339(5):313-20. [pmid: 9682045].
Griffin G. Are oral betamimetics effective maintenance therapies after threatened preterm labor?. American Family Physician. 2007;75(5):648-50. [pmid: 17375508].
Groome LJ, Goldenberg RL, Cliver SP, et al. Neonatal periventricular-intraventricular hemorrhage after maternal beta-sympathomimetic tocolysis. The March of Dimes Multicenter Study Group. Am J Obstet Gynecol. Oct. 1992;167(4 Pt 1):873-9. [pmid: 1415418].
Hatjis CG, Swain M. Systemic tocolysis for premature labor is associated with an increased incidence of pulmonary edema in the presence of maternal infection. Am J Obstet Gynecol. Sep. 1988;159(3):723-8. [pmid: 3421269].
Kuhlmann RS, Cruikshank DP. Maternal trauma during pregnancy. Clinical Obstetrics and Gynecology. 1994;37(2):274-93. [pmid: 8033443].
Norton ME. Teratogen update: Fetal effects of indomethacin administration during pregnancy. Teratology. 1997;56(4):282-92. [pmid: 9408979].
Obradovich JH, Woods DD. Users as designers: how people cope with poor HCI design in computer-based medical devices. Human Factors. Dec. 1996;38(4):574-92. [pmid: 8976622].
Palta M, Sadek M, Lim TS, et al. Association of tocolytic therapy with antenatal steroid administration and infant outcomes. Newborn Lung Project. Am J Perinatol. Feb. 1998;15(2):87-92. [pmid: 9514131].
Richards NA, Yentis SM. Anaesthesia, analgesia and peripartum management in women with preexisting cardiac and respiratory disease. Fetal and Maternal Medicine Review. 2006;17(4):327-47.
Multiple gestations. Clin Perinatol. Jun. 2005;32(2):xi.

## Full-Text: Abstract or full-text not in English (either no or cannot tell)/ insufficient information provided in abstract (full-text not in English) (n=12)

Chimura T. [Clinical studies on imipenem/cilastatin sodium in the early therapy of preterm premature rupture of the membrane or threatened abortion and premature delivery]. [Japanese]. Japanese Journal of Antibiotics. Aug. 1992;45(8):1023-8. [pmid: 1433891].
Criee CP, Laier-Groeneveld G. Beta<sub>2</sub> sympathicomimetic agents. [German]. Internist. 1995;36(9):918-23. [pmid: 7591618].
Grospietsch G. [Medical tocolysis in threatening premature labor: what is safe in therapy?]. Gynakologe. Aug. 1991;24(4):188-97. [pmid: 1682223].
Kishikawa T, Kawarabayashi T, Sugimori H. [Combined therapy with magnesium sulfate and terbutaline for preterm labor tocolysis]. [Japanese]. Nippon Sanka Fujinka Gakkai Zasshi - Acta Obstetrica et Gynaecologica Japonica. Sep. 1986;38(9):1670-3.
Lam F, Gill PJ, Smith M. Comparison of portable subcutaneous terbutaline pump and oral terbutaline treatment for long-term tocolysis: A randomized clinical trial. Abstract 400. Eighth annual meeting—Society of Perinatal Obstetricians. 1988.
Lam F, Klutz R. The pharmacokinetic impact of the pharmacodynamic effect of subcutaneous terbutaline in the treatment of preterm labor. Continental Gynecologic Society Annual Meeting. 1989:1-22.
Lowenberg E, Escobedo F, Garcia P, et al. [The treatment of threatened preterm labor. A comparative study between 2 beta-mimetics]. [Spanish]. Ginecologia y Obstetricia de Mexico. May. 1988;56:111-5. 1988 May.:111-5. [pmid: 3154223].
Morales WJ, Marko BH. Adjusted oral terbutaline vs subcutaneous terbutaline pump therapy in the management of preterm labor. Proceedings of 10th Annual Meeting of Society of Perinatal Obstetricians. 1990 Jan 23 27. Houston, Texas, USA. 1990:149.
Vargas G, Lowenberg E. Terburalina. Un nuevo utero-inhibidor. Ginec Obstet Mex. 1974;36:75. [pmid: 4430451].
Woodland MB, Smith C, Byers J, et al. Clinical comparison of oral nifedipine and subcutaneous terbutaline use for initial tocolysis. Proceedings of 10th Annual Meeting of Society of Perinatal Obstetricians. 1990 Jan 23 27. Houston, Texas, USA. 1990:523.
Institute for Clinical Systems Improvement (ICSI). Tocolytic therapy for preterm labor. Bloomington, MN. ICSI. 2000;49.
Prevention program boosts preterm labor outcomes. Home Care Case Management. Feb. 1997;4(2):21-3. insert.

## Full-Text: Unavailable (n=7)

Ingemarsson I. Terbutaline treatment of premature labor - Low incidence of severe side effects. 10th World Congress of Gynecology and Obstetrics. 1982. p, Abstract 1213.
Jones J, Istwan. Pregnancy prolongation after discontinuation of subcutaneous tocolysis in singleton gestations. Obstet Gynecol. 2003;101:4.
Lam F, Graves Wk, Peacock WG. Side effects of beta-mimetic administration: Tocolytic agents. ACOG Districts VIII and IX Meeting. Las Vegas, Nevada. 1987.
McGettigan M, Bhutani V, Rathbone A. Prenatal b-mimetic exposure of the newborn: maternal oral vs. continuous infusion therapy. Pediatr Res. 1991;30:62A. [pmid: 1891282].
Moise KJ, Dorman K, Giebel R. A randomized study of intravenous versus subcutaneous/oral terbutaline in the treatment of preterm labor. Seventh Annual Meeting of the Society of Perinatal Obstetricians. 1987. p. Abstract #276.
Sharif D, Huhta J, Moise KJ. Changes in fetal hemodynamics with preterm labor and terbutaline. Seventh Annual Meeting of the Society of Perinatal Obstetricians. 1987. p. Abstract 140.
Watson P, Shapiro K, Fure J. Betamimetic-associated pulmonary edema: Time and dose relationships. Fifth annual meeting, Society of Perinatal Obstetricians. 1985. p. Abstract #68.

## Full-Text: Does not include women with arrested preterm labor (n=4)

Besinger RE, Moniak CW, Paskiewicz LS, et al. The effect of tocolytic use in the management of symptomatic placenta previa. American Journal of Obstetrics & Gynecology. Jun. 1995;172(6):1770-5. [pmid: 7778631].
Estaban-Altirriba J. Treatment of fetal distress, in Tocolytic Agents. In Society of Perinatal Obstetricians. Proceedings of a Symposium on Tocolytic Therapy. 1980:69-75.
Parsons MT, Owens CA, Spellacy WN. Thermic effects of tocolytic agents: decreased temperature with magnesium sulfate. Obstetrics & Gynecology. Jan. 1987;69(1):88-90. [pmid: 3796926].
Towers CV, Pircon RA, Heppard M, et al. Is tocolysis safe in the management of third-trimester bleeding?. American Journal of Obstetrics and Gynecology. 1999;180(6 I):1572-8. [pmid: 10368505].

## Full-Text: Does not assess one of the specified outcomes (n=3)

Berg G, Andersson RG, Ryden G. Beta-adrenoceptor function of leukocytes in pregnant women treated with terbutaline for preterm labor. Acta Obstetricia et Gynecologica Scandinavica. 1984;63(6):555-61. [pmid: 6095584].
Berkus M, Langer O, Kigby K. Effect of terbutaline pump on maternal glucose metabolism. Am J Obstet Gynecol. 1999;180(Suppl. 1):S41.
Towers CV, Kaminskas CM, Garite TJ, et al. Pulmonary injury associated with antepartum pyelonephritis: can patients at risk be identified?. Am J Obstet Gynecol. Apr. 1991;164(4):974-8. [pmid: 2014849].

## Full-Text: Companion article with no additional data (n=2)

Ambrose S, Jacques D, Stanziano. Clinical and economic outcomes of continuous subcutaneous tocolysis. Obstet Gynecol. 2001;97:47.
Wenstrom K, Weiner C, Merrill D, et al. A placebo-controlled trial of the terbutaline (T) pump for prevention of preterm delivery. [abstract]. American Journal of Obstetrics and Gynecology. 1995;172:416.

## Full-Text: Study design does not allow for an evaluation of SQ terbutaline pump as the sole maintenance tocolytic therapy (n=1)

Viscarello R, Griffith S, Charney. Outpatient management of higher order multiples with a comprehensive care plan improves outcome. Obstet Gynecol. 2002;99:71.