# Scientific Information Packet Request

Requests for Scientific Information Packets (SIPs) were made from the following companies:

- M Infusion Therapy
- AAIPharma Inc.
- Akorn, Inc.
- Abraxis Pharmaceuticals (APP Pharmaceuticals)
- AstraZeneca Pharmaceuticals, LP
- Baxter Healthcare Corp
- Becton, Dickinson and Company
- Bedford Laboratories Inc.
- BREG, Inc.
- C.R. Bard, Inc.
- Disetronic Medical Systems AG
- Disetronic Medical Systems Inc.
- Hikma Pharmaceuticals (USA) Ltd.
- I-Flow Corporation
- Impax Laboratories, Inc.
- International Infusion, LLC (Intra Pump Infusion Systems)
- Lannett Company, Inc.
- MarCal Medical, Inc.
- Medtronic Diabetes
- Medtronic MiniMed, Inc.
- Novartis Pharmaceuticals Corporation
- RMS Medical Products
- Roche Diagnostics
- Sanofi Aventis US
- Sorenson Medical Inc.
- Tandem Medical Equipment Inc.
- Teva Pharmaceuticals USA

Responses were received from the following companies:

- AAIPharma Inc.
- Abraxis Pharmaceuticals (APP Pharmaceuticals)
- Baxter Healthcare Corp
- BREG, Inc.
- C.R. Bard, Inc.
- Impax Laboratories, Inc.
- International Infusion, LLC (Intra Pump Infusion Systems)
- RMS Medical Products
- Roche Diagnostics
- Sanofi Aventis US