# Grey Literature Search

Search Dates: Nov. 27, 2009; Nov 29, 2009; Dec 31, 2009; Jan 2, 2010

## Statistics

Canadian perinatal health report. Public Health Agency of Canada. 2008. http://www.phac-aspc.gc.ca/publicat/2008/cphr-rspc/pdf/cphr-rspc08-eng.pdf.
Alberta Reproductive Health: Pregnancies and Births Table Update, 2005, Alberta Health & Wellness; Alberta Perinatal Health Program. 2005. http://www.health.alberta.ca/documents/Reproductive-Health-2005.pdf.

## Systematic Reviews/Health Technology Assessments

Screening to prevent spontaneous preterm birth: systematic reviews of accuracy and effectiveness literature with economic modelling, Health Technol Assess. 2009;13(43):1-627. Summary: http://www.hta.ac.uk/execsumm/summ1343.shtml Full text: http://www.hta.ac.uk/fullmono/mon1343.pdf.
Continuous subcutaneous terbutaline infusion for treatment of preterm labor. HAYES, Inc. Healthcare Technology Brief Publication. 2006. http://www.crd.york.ac.uk/CRDWeb/ShowRecord.asp?ID=32009100278 Subscription required.
Management of preterm labor, Evidence report/Technology assessment no 18. 2000. http://www.ncbi.nlm.nih.gov/bookshelf/br.fcgi?book=hserta&part=A26682.

## Safety

Short-acting beta agonists and risk of myocardial ischaemia. Final SPC and PL wording agreed by PhVWP. October. 2009. http://www.hma.eu/fileadmin/dateien/Human_Medicines/CMD_h_/Product_Information/PhVWP_Recommendations/SABAs/CMDh-PhVWP-008-2009-Rev0a.pdf.
ICU MEDICAL, INC. ORBIT 90″ SUBCUTANEOUS INFUSION SET, Device leak. 2006. http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfMAUDE/Detail.CFM?MDRFOI__ID=795454.
CADD-MICRO TERBUTALINE PUMP SHOWER BAG, Injury. 2005. http://www.accessdata.fda.gov/scripts/cdrh/cfdocs/cfMAUDE/Detail.CFM?MDRFOI__ID=578910.
Warning on use of terbutaline sulfate for preterm labor, JAMA. 1998;279(1):9. http://jama.ama-assn.org/cgi/content/extract/279/1/9-a.

## Guidelines

Terbutaline pump for preterm labor, Aetna. 25. Aug. 2009. http://www.aetna.com/cpb/medical/data/400_499/0468.html.
Management of Labour, ICSI. May. 2009. http://www.icsi.org/labor/labor__management_of__full_version__2.html.
Obstetric and Medical Complications, Guidelines for perinatal care. ACOG. 2007. http://www.acog.org/publications/guidelinesForPerinatalCare/gpc-175.pdf.
Management of preterm labor. http://www.acog.org/publications/pdfs/pb043.pdf.
Tocolytic drugs for women in preterm labour, RCOG. 2002. http://www.rcog.org.uk/files/rcog-corp/GT1BTocolyticDrug2002revised.pdf.

## Conference Literature

Continuous Subcutaneous Terbutaline Therapy Improves Outcome in Pregnancies Complicated by Preterm Labour. Presented at ACOG. 11 May 2009. [Presentation title: Using Meta-Analysis Methodology to Evaluate Treatment of Preterm Labor. Abstract 79]. http://www.peerviewpress.com/continuous-subcutaneous-terbutaline-therapy-improves-outcome-pregnancies-complicated-preterm-labour-presented-acog.

## Economics

Ambrose S, Rhea DJ, Istwan NB, Collins A, Stanziano G. Clinical and economic outcomes of preterm labor management: inpatient vs outpatient, J Perinatol. 2004;24(8):515-9. Economic evaluation: http://www.crd.york.ac.uk/CRDWeb/ShowRecord.asp?View=Full&ID=22004009091.
Fleming A, Bonebrake R, Istwan N, Rhea D, Coleman S, Stanziano G. Pregnancy and economic outcomes in patients treated for recurrent preterm labor, J Perinatol. 2004;24(4):223-7. Economic evaluation: http://www.crd.york.ac.uk/CRDWeb/ShowRecord.asp?View=Full&ID=22004006413.
Morrison JC, Chauhan SP, Carroll CS Sr, Bofill JA, Magann EF. Continuous subcutaneous terbutaline administration prolongs pregnancy after recurrent preterm labor, Am J Obstet Gynecol. 2003;188(6):1460-5. Economic evaluation : http://www.crd.york.ac.uk/CRDWeb/ShowRecord.asp?View=Full&ID=22003009556.
Lam F, Istwan NB, Jacques D, Coleman SK, Stanziano GJ. Managing perinatal outcomes: the clinical benefit and cost-effectiveness of pharmacologic treatment of recurrent preterm labor, Manag Care. 2003;12(7):39-46. Full text: http://www.managedcaremag.com/archives/0307/0307.peer_terbutaline.pdf Economic evaluation: http://www.crd.york.ac.uk/CRDWeb/ShowRecord.asp?View=Full&ID=22003006379.
Lam F, Bergauer NK, Jacques D, Coleman SK, Stanziano GJ. Clinical and cost-effectiveness of continuous subcutaneous terbutaline versus oral tocolytics for treatment of recurrent preterm labor in twin gestations, J Perinatol. 2001;21(7):444-50. Economic evaluation: http://www.crd.york.ac.uk/CRDWeb/ShowRecord.asp?View=Full&ID=22002006321.

## General/Miscellaneous

Note: Oregon Centre for Evidence-Based Policy appears to have done an evaluation on this topic, but I can't find it on their Web site. You may wish to follow up with Mark Gibson, Deputy Director, gibsomar@ohsu.edu Source info http://docs.google.com/viewer?a=v&q=cache:0swFA5nHTqwJ:www.ecri.org/Documents/CERC/Gibson_Slides.pdf+Terbutaline+%2Bpreterm&hl=en&pid=bl&srcid=ADGEESiy9CSSqC5hjlZLxayoNVAQl9eIrd2xxfdEr86KQ-f_S6EVlmVX1HF3z_k9eThgxJc0N2Mr9thxd1UbF8WzukHgJszLh5oVxaKLX2Hy9tlDXcSOsNAY29X5E3yKXPmqAcVXLNvE&sig=AHIEtbSsSIQGqbdzwHPWmw2u5XB-ZwzDnA
Parenteral tocolytic therapy, Cigna Medical Coverage Policy. Sep. 2009. http://www.cigna.com/customer_care/healthcare_professional/coverage_positions/medical/mm_0379_coverageposition_terbutaline_pump_and_tocolytic_therapy.pdf.
After arrest of preterm labor, is continuous subcutaneous infusion of terbutaline effective treatment to prevent preterm birth?. http://www.infopoems.com/search/?query=terbutaline Subscription required.
Preterm labor, Medscape. 2009. http://emedicine.medscape.com/article/260998-overview.
Determinants and prevention of low birth weight: a synopsis of the evidence. Institute for Health Economics. Dec. 2008. http://www.ihe.ca/documents/IHE%20Report%20LowBirthWeight%20final.pdf.
Tocoylsis with intravenous or subcutaneous terbutaline. Blue Cross. North Caroline. Dec. 2008. http://www.bcbsnc.com/assets/services/public/pdfs/medicalpolicy/tocolysis_with_intravenous_or_subcutaneous_terbutaline.pdf.
Born too soon: the continuing challenge of preterm labor and birth in the United States, J Midwifery Womens Health. 2007;52(3):281-90. PubMed: http://www.ncbi.nlm.nih.gov/pubmed/17467595.
Preterm labour and birth: a survey of clinical practice regarding use of tocolytics, antenatal corticosteroids, and progesterone, JOGC. 2007. http://www.sogc.org/jogc/abstracts/full/200702_Obstetrics_1.pdf.
Preterm labour, Merck. 2005. http://www.merck.com/mmpe/sec18/ch264/ch264f.html.
Frequently asked questions on tocolytics, BJOG. 1. 2005;112:94-6. http://www.porodnice.cz/upload/predcasny-porod/literatura/Frequently_askd_Q_on_tocolytics.pdf.
Sanchez-Ramos L, Huddleston J. The therapeutic value of maintenance tocolysis: an overview of the evidence, Clinics Perinatol. 2003;30(4):841-54. PubMed: http://www.ncbi.nlm.nih.gov/pubmed/14714925.
Terbutaline studies. 2003. http://www.twinslist.org/tablest.html.
Subcutaneous terbutaline pump in triplet gestation. Keith, Blickstien, editors. Triplet pregnancies and their consequences. Parthenon Publishing Group. 2002:181-202. http://books.google.com/books?hl=en&lr=&id=1aAtl4zt5SMC&oi=fnd&pg=PA181&dq=%22Terbutaline+pump%22+%2Bpreterm&ots=9rflddzapK&sig=PKMAevXgDOfTdcCcn7vj9Kasjy8#.
Management of preterm labour, JAOA. 2001;101(2 Suppl):S14-8. http://www.jaoa.org/cgi/reprint/101/2_suppl/14S.pdf Discusses terbutaline pump therapy.
Gyetvai K, Hannah ME, Hodnett ED, Ohlsson A. Tocolytics for preterm labor: a systematic review, Obstetrics and Gynecology. 1999;94(5 Part 2):869-877. PubMed: http://www.ncbi.nlm.nih.gov/pubmed/10546776?dopt=Abstract. Critical Appraisal: http://www.crd.york.ac.uk/CRDWeb/ShowRecord.asp?View=Full&ID=11999002142.
Meirowitz NB, Ananth CV, Smulian JC, Vintzileos AM. Value of maintenance therapy with oral tocolytics: a systematic review, Journal of Maternal-Fetal Medicine. 1999;8(4):177-83. PubMed: http://www.ncbi.nlm.nih.gov/pubmed/10406302?dopt=Abstract. Critical Appraisal: http://www.crd.york.ac.uk/CRDWeb/ShowRecord.asp?View=Full&ID=11999004436.
Shellhaas, et al. Ambulatory management of preterm labour, Clin Obstet Gynecol. 1998;41(3):491-502. http://www.ncbi.nlm.nih.gov/pubmed/9742347.
FDA Advisory Cttee for Reproductive Health Drugs. 1998. http://www.fda.gov/OHRMS/DOCKETS/AC/98/transcpt/3407t1.rtf.
Cowan M. Home care of the pregnant woman using terbutaline, MCN Am J Matern Child Nurs. 1993;18(2):99-105. http://journals.lww.com/mcnjournal/Citation/1993/03000/Home_Care_Of_the_Pregnant_Woman_Using_Terbutaline.8.aspx.
Women's experiences using terbutaline pump therapy for the management of preterm labor, Dissertation. 1993. http://nursinglibrary.org/Portal/main.aspx?pageid=4024&sid=9372.
Comanagement of the patient on subcutaneous terbutaline pump therapy, J Nurse Midwifery. 1991;36(3):204-8. http://www.sciencedirect.com/science?_ob=ArticleURL&_udi=B6T8N-4G0105T-15B&_user=10&_rdoc=1&_fmt=&_orig=search&_sort=d&_docanchor=&view=c&_searchStrId=1150447764&_rerunOrigin=scholar.google&_acct=C000050221&_version=1&_urlVersion=0&_userid=10&md5=1424a1cfe166517951e6cc1113e16f96.

## Regulatory

Canada

Licence No.: 7709 Type: Device Group Family

Licence Section
Device Class | First Issue Date | Licence Name
2 | 1999-07-12 | SOF-SET INFUSION SET

Device Section | | Identifier Section
First Issue Date | Device Name | First Issue Date | Device Identifier
1999-07-12 | SOF-SET INFUSION SET | 1999-07-12 | MMT-112
1999-07-12 | SOF-SET INFUSION SET | 2002-05-06 | MMT-111
1999-07-12 | SOF-SET INFUSION SET | 2009-03-10 | MMT-111T
1999-07-12 | SOF-SET INFUSION SET | 2009-03-10 | MMT-112T

Licence No.: 13631 Type: Single Device

Licence Section
Device Class | First Issue Date | Licence Name
2 | 1999-11-02 | SOF-SET MICRO QR INFUSION SET

Device Section | | Identifier Section
First Issue Date | Device Name | First Issue Date | Device Identifier
1999-11-02 | SOF-SET MICRO QR | 1999-11-02 | MMT-320
1999-11-02 | SOF-SET MICRO QR | 1999-11-02 | MMT-321
1999-11-02 | SOF-SET MICRO QR | 2009-03-10 | MMT-320T
1999-11-02 | SOF-SET MICRO QR | 2009-03-10 | MMT-321T

Licence No.: 14508 Type: Device Group

Licence Section
Device Class | First Issue Date | Licence Name
2 | 1999-11-23 | MINIMED SOF-SET ULTIMATE QR INFUSION SET

Device Section | | Identifier Section
First Issue Date | Device Name | First Issue Date | Device Identifier
1999-11-23 | MINIMED SOF-SET ULTIMATE QR | 1999-11-23 | MMT-315
1999-11-23 | MINIMED SOF-SET ULTIMATE QR | 1999-11-23 | MMT-316
1999-11-23 | MINIMED SOF-SET ULTIMATE QR | 2009-03-10 | MMT-315T
1999-11-23 | MINIMED SOF-SET ULTIMATE QR | 2009-03-10 | MMT-316T

Licence No.: 37241 Type: Single Device

Licence Section
Device Class | First Issue Date | Licence Name
2 | 2002-04-05 | MINIMED PARADIGM SOF-SET ULTIMATE QR MODEL NO. 317, 318

Device Section | | Identifier Section
First Issue Date | Device Name | First Issue Date | Device Identifier
2002-04-05 | MINIMED PARADIGM SOF-SET ULTIMATE QR INFUSION SET | 2002-04-05 | MMT-317
2002-04-05 | MINIMED PARADIGM SOF-SET ULTIMATE QR INFUSION SET | 2002-04-05 | MMT-318
2002-04-05 | MINIMED PARADIGM SOF-SET ULTIMATE QR INFUSION SET | 2009-03-16 | MMT-317T
2002-04-05 | MINIMED PARADIGM SOF-SET ULTIMATE QR INFUSION SET | 2009-03-16 | MMT-318T

Licence No.: 37244 Type: Single Device

Licence Section
Device Class | First Issue Date | Licence Name
2 | 2002-04-05 | MINIMED PARADIGM SOF-SET ULTIMATE QR MODEL NO. 324, 325

Device Section | | Identifier Section
First Issue Date | Device Name | First Issue Date | Device Identifier
2002-04-05 | MINIMED PARADIGM SOF-SET ULTIMATE QR INFUSION SET | 2002-04-05 | MMT-324
2002-04-05 | MINIMED PARADIGM SOF-SET ULTIMATE QR INFUSION SET | 2002-04-05 | MMT-325
2002-04-05 | MINIMED PARADIGM SOF-SET ULTIMATE QR INFUSION SET | 2009-03-16 | MMT-325T

Licence No.: 11270 Type: Device Family

Licence Section
Device Class | First Issue Date | Licence Name
2 | 1999-09-02 | DISETRONIC CARTRIDGES FOR MICRODOSE INFUSION PUMPS

Device Section | | Identifier Section
First Issue Date | Device Name | First Issue Date | Device Identifier
2005-07-06 | DISETRONIC PLASTIC CARTRIDGES | 2007-08-28 | 04567463001
2005-07-06 | DISETRONIC PLASTIC CARTRIDGES | 2007-08-28 | 04567528001
2005-07-06 | DISETRONIC PLASTIC CARTRIDGES | 2007-08-28 | 04923707001
2005-07-06 | DISETRONIC PLASTIC CARTRIDGES | 2008-04-16 | 04854047001
2005-07-06 | DISETRONIC PLASTIC CARTRIDGES | 2008-04-24 | 04949064001
2005-07-06 | DISETRONIC PLASTIC CARTRIDGES | 2008-04-24 | 04949935001
2005-07-06 | DISETRONIC PLASTIC CARTRIDGES | 2008-04-24 | 05206073001

Grey Literature Search: SRC

Search Date: April 8, 2010

Regulatory Information

FDA

Health Canada

Authorized Medicines for EU

Clinical Trial Registries

ClinicalTrials.gov

Current Controlled Trials

Clinical Study Results

WHO Clinical Trials

Abstracts and Conference Papers

Conference Papers Index

Scopus

Grants and Federally Funded Research

NIH RePORTER (a searchable database of federally funded biomedical research projects conducted at universities, hospitals, and other research institutions)

HSRPROJ (a database providing access to ongoing grants and contracts in health services research)

Other Miscellaneous Sources

Hayes, Inc. Health Technology Assessment

NY Academy of Medicine's Grey Literature Index