# Search Strategies

Database: Ovid MEDLINE(R) In-Process & Other Non-Indexed Citations and Ovid MEDLINE(R) <1950 to 2009 Dec Week 1> (updated to April 1, 2011) Search Strategy
1. exp Obstetric Labor, Premature/ (14094)
2. (PTL or PTB or RPTL).ti,ab. (2396)
3. ((premature* or pre-mature* or preterm or pre-term or early) adj5 (labor* or labour* or birth* or deliver*)).ti,ab. (32212)
4. ((premature* or pre-mature* or preterm or pre-term or early) adj5 ((uterine or uterus) adj2 contract*)).ti,ab. (306)
5. Tocolysis/ or Tocolytic Agents/ (1876)
6. (tocolysis or tocolytic*).ti,ab. (2856)
7. 1 or 2 or 3 or 4 or 5 or 6 (40062)
8. exp Terbutaline/ (2921)
9. (Terbutalin* or Brethaire or Brethine or Bricanyl or “BRN 2370513” or “EINECS 245-385-8” or “UNII-N8ONU3L3PG”).ti,ab. (3089)
10. (23031 25 6 terbutaline or 23031 32 5 terbutaline sulfate).rn. (2921)
11. 8 or 9 or 10 (3761)
12. exp Injections, Subcutaneous/ (31708)
13. exp Infusion Pumps/ (9822)
14. exp Home Infusion Therapy/ (555)
15. exp Infusions, Parenteral/ (75058)
16. (subcutaneous* or SubQ or sub-cutaneous* or pump or pumps or infuse or infused or infuses or infusing or infusion* or infuser*).ti,ab. (354453)
17. ((home adj3 therapy) or (home adj3 therapies) or (home adj3 tocoyl*) or (home-based adj3 therapy) or (home-based adj3 therapies) or (home-based adj3 tocoyl*)).ti,ab. (2249)
18. ((maintenance adj3 therapy) or (maintenance adj3 therapies) or (maintenance adj3 therapeutic) or (maintenance adj3 treatment*) or (maintenance adj3 tocoly*) or (supportive adj3 therapy) or (supportive adj3 therapies) or (supportive adj3 treatment*) or (supportive adj3 tocoyls*) or (outpatient adj3 therapy) or (outpatient adj3 therapies) or (outpatient* adj3 treatment*) or (outpatient* adj3 tocoly*)).ti,ab. (27705)
19. ((long-term adj therapy) or (long-term adj therapies) or (long-term adj therapeutic) or (long-term adj treatment*) or (long-term adj management) or (long-term adj tocoly*) or (longterm adj therapy) or (longterm adj therapies) or (longterm adj therapeutic) or (longterm adj treatment*) or (longterm adj management) or (longterm adj tocoly*)).ti,ab. (23491)
20. 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 (457526)
21. 11 and 20 (694)
22. 7 and 21 (158)
23. from 22 keep 1-158 (158)

Database: EMBASE <1980 to 2009 Week 49> (Updated to April 1, 2011) Search Strategy
1. exp premature labor/ (12859)
2. (PTL or PTB or RPTL).ti,ab. (1981)
3. ((Premature* or pre-mature* or preterm or pre-term or early) adj5 (labor* or labour* or birth* or deliver*)).ti,ab. (24223)
4. ((Premature* or pre-mature* or preterm or pre-term or early) adj5 ((uterine or uterus) adj2 contract*)).ti,ab. (243)
5. exp Tocolysis/ (2223)
6. (tocolysis or tocolytic*).ti,ab. (2419)
7. 1 or 2 or 3 or 4 or 5 or 6 (30904)
8. exp terbutaline/ (8346)
9. exp terbutaline sulfate/ (492)
10. (23031 25 6 or 23031 32 5).rn. (8627)
11. (Terbutalin* or Brethaire or Brethine or Bricanyl or “BRN 2370513” or “EINECS 245-385-8” or “UNII-N8ONU3L3PG”).ti,ab. (2721)
12. (Terbutalin* or Brethaire or Brethine or Bricanyl).tn. (1416)
13. 8 or 9 or 11 or 12 (8802)
14. exp subcutaneous drug administration/ (72002)
15. exp infusion pump/ (2755)
16. exp infusion/ (26593)
17. (subcutaneous* or SubQ or sub-cutaneous* or pump or pumps or infuse or infused or infuses or infusing or infusion* or infuser*).ti,ab. (285686)
18. ((home adj3 therapy) or (home adj3 therapies) or (home adj3 tocoyl*) or (home-based adj3 therapy) or (home-based adj3 therapies) or (home-based adj3 tocoyl*)).ti,ab. (1578)
19. ((maintenance adj3 therapy) or (maintenance adj3 therapies) or (maintenance adj3 therapeutic) or (maintenance adj3 treatment*) or (maintenance adj3 tocoly*) or (supportive adj3 therapy) or (supportive adj3 therapies) or (supportive adj3 treatment*) or (supportive adj3 tocoyls*) or (outpatient adj3 therapy) or (outpatient adj3 therapies) or (outpatient* adj3 treatment*) or (outpatient* adj3 tocoly*)).ti,ab. (23804)
20. ((long-term adj therapy) or (long-term adj therapies) or (long-term adj therapeutic) or (long-term adj treatment*) or (long-term adj management) or (long-term adj tocoly*) or (longterm adj therapy) or (longterm adj therapies) or (longterm adj therapeutic) or (longterm adj treatment*) or (longterm adj management) or (longterm adj tocoly*)).ti,ab. (21021)
21. 14 or 15 or 16 or 17 or 18 or 19 or 20 (392514)
22. 13 and 21 (1163)
23. 7 and 22 (188)
24. from 23 keep 1-188 (188)

CINAHL 2009 Dec 7

# | Query | Results
S24 | S12 AND S23 | 32
S23 | S13 OR S14 OR S16 OR S17 OR S18 OR S19 OR S22 | 30893
S22 | (MH “Infusions, Parenteral+”) | 4186
S21 | S12 AND S20 | 32
S20 | S13 OR S14 OR S15 OR S16 OR S17 OR S18 OR S19 | 30863
S19 | TX (long-term W1 therapy) or (long-term W1 therapies) or (long-term W1 therapeutic) or (long-term W1 treatment*) or (long-term W1 management) or (long-term W1 tocoly*) or (longterm W1 therapy) or (longterm W1 therapies) or (longterm W1 therapeutic) or (longterm W1 treatment*) or (longterm W1 management) or (longterm W1 tocoly*)) | 4365
S18 | TX (maintenance N3 therapy) or (maintenance N3 therapies) or (maintenance N3 therapeutic) or (maintenance N3 treatment*) or (maintenance N3 tocoyl*) or (supportive N3 therapy) or (supportive N3 therapies) or (supportive N3 treatment*) or (supportive N3 tocoly*) or (outpatient* N3 therapy) or (outpatient* N3 therapies) or (outpatient* N3 therapeutic) or (outpatient* N3 treatment*) or (outpatient* N3 tocoyl*) | 4252
S17 | TX ( home N3 therapy) or (home N3 therapies) or (home N3 tocoly*) or (home-based N3 therapy) or (home-based N3 therapies) or (home-based N3 tocoly*) | 2453
S16 | TX subcutaneous* or SubQ or sub-cutaneous* or pump or pumps or infuse or infused or infuses or infusing or infusion* or infuser | 21255
S15 | (MH “Infusions, Parenteral”) | 276
S14 | (MH “Infusion Pumps+”) | 1748
S13 | (MH “Injections, Subcutaneous+”) | 1188
S12 | S8 AND S11 | 63
S11 | S9 or S10 | 206
S10 | TX Terbutalin* or Brethaire or Brethine or Bricanyl or “BRN 2370513” or “EINECS 245-385-8” or “UNII-N8ONU3L3PG” | 206
S9 | (MH “Terbutaline”) | 137
S8 | S1 OR S2 OR S3 OR S4 OR S5 OR S6 OR S7 | 5924
S7 | TX Tocolytic OR tocolysis | 431
S6 | “TX ( (premature* N5 (uterine N2 contract*)) OR (pre-mature* N5 (uterine N2 contract*)) OR (preterm N5 (uterine N2 contract*)) OR (pre-term N5 (uterine N2 contract*)) OR early N5 (uterine N2 contract*)) ) or TX ( (premature* N5 (uterus N2 contract*)) OR (pre-mature* N5 (uterus N2 contract*)) OR (preterm N5 (uterus N2 contract*)) OR (pre-term N5 (uterus N2 contract*)) OR (early N5 (uterus N2 contract*)) )” | 0
S5 | TX (early N5 labor*) OR (early N5 labour*) OR (early N5 birth*) OR (early N5 deliver*) | 1189
S4 | TX ( (preterm N5 labor*) or (preterm n5 labour*) or (preterm n5 birth*) or (preterm n5 deliver*) ) or TX ( (pre-term N5 labor*) or (pre-term n5 labour*) or (pre-term n5 birth*) or (pre-term n5 deliver*) ) | 3453
S3 | TX ( (premature* N5 labor*) or (premature* n5 labour*) or (premature* n5 birth*) or (premature* n5 deliver*) ) or TX ( (pre-mature* N5 labor*) or (pre-mature* n5 labour*) or (pre-mature* n5 birth*) or (pre-mature* n5 deliver*) ) | 2397
S2 | TX PTL or PTB or RPTL | 180
S1 | (MH “Labor, Premature”) | 1539

Cochrane Library 2009, Issue 4 (updated to April 1, 2011)

ID | Search | Hits
#1 | MeSH descriptor Obstetric Labor, Premature explode all trees | 782
#2 | (PTL or PTB or RPTL):ti,ab,kw | 56
#3 | (premature* NEAR/5 labor*) OR (premature* NEAR/5 labour*) OR (premature* NEAR/5 birth*) OR (premature* NEAR/5 deliver*):ti,ab,kw | 1744
#4 | (premature NEAR/5 (uterus NEAR/2 contract*)):ti,ab,kw or (premature NEAR/5 (uterine NEAR/2 contract*)):ti,ab,kw | 15
#5 | (pre NEXT mature* NEAR/5 labor*) OR (pre NEXT mature* NEAR/5 labour*) OR (pre NEXT mature* NEAR/5 birth*) OR (pre NEXT mature* NEAR/5 deliver*):ti,ab,kw | 0
#6 | ((pre NEXT mature) NEAR/5 (uterus NEAR/2 contract*)):ti,ab,kw or ((pre NEXT mature) NEAR/5 (uterine NEAR/2 contract*)):ti,ab,kw | 0
#7 | (preterm NEAR/5 labor*) OR (preterm NEAR/5 labour*) OR (preterm NEAR/5 birth*) OR (preterm NEAR/5 deliver*):ti,ab,kw | 1466
#8 | (preterm NEAR/5 (uterus NEAR/2 contract*)):ti,ab,kw or (preterm NEAR/5 (uterine NEAR/2 contract*)):ti,ab,kw | 15
#9 | (pre NEXT term NEAR/5 labor*) OR (pre NEXT term NEAR/5 labour*) OR (pre NEXT term NEAR/5 birth*) OR (pre NEXT term NEAR/5 deliver*):ti,ab,kw | 28
#10 | ((pre NEXT term) NEAR/5 (uterus NEAR/2 contract*)):ti,ab,kw or ((pre NEXT term) NEAR/5 (uterine NEAR/2 contract*)):ti,ab,kw | 0
#11 | (early NEAR/5 labor*) OR (early NEAR/5 labour*) OR (early NEAR/5 birth*) OR (early NEAR/5 deliver*) :ti,ab,kw | 602
#12 | (early NEAR/5 (uterus NEAR/2 contract*)):ti,ab,kw or (early NEAR/5 (uterine NEAR/2 contract*)):ti,ab,kw | 9
#13 | MeSH descriptor Tocolysis explode all trees | 92
#14 | (tocolysis or tocolytic*):ti,ab,kw | 479
#15 | (#1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14) | 3147
#16 | MeSH descriptor Terbutaline explode all trees | 686
#17 | (Terbutalin* or Brethaire or Brethine or Bricanyl or “BRN 2370513” or “EINECS 245-385-8” or “UNII-N8ONU3L3PG”):ti,ab,kw | 1220
#18 | (#16 OR #17) | 1220
#19 | MeSH descriptor Injections, Subcutaneous explode all trees | 2896
#20 | MeSH descriptor Infusion Pumps explode all trees | 806
#21 | MeSH descriptor Home Infusion Therapy explode all trees | 41
#22 | MeSH descriptor Infusions, Parenteral explode all trees | 9362
#23 | (subcutaneous* or SubQ or (sub NEXT cutaneous*) or pump or pumps or infuse or infused or infuses or infusing or infusion* or infuser*):ti,ab,kw | 38786
#24 | (home NEAR/3 therapy) or (home NEAR/3 therapies) or (home NEAR/3 tocoyl*) or ((home NEXT based) NEAR/3 therapy) or ((home NEXT based) NEAR/3 therapies) or ((home NEXT based) NEAR/3 tocoyl*):ti,ab,kw | 657
#25 | (maintenance NEAR/3 therapy) or (maintenance NEAR/3 therapies) or (maintenance NEAR/3 therapeutic) or (maintenance NEAR/3 treatment*) or (maintenance NEAR/3 tocoly*) or (supportive NEAR/3 therapy) or (supportive NEAR/3 therapies) or (supportive NEAR/3 treatment*) or (supportive NEAR/3 tocoyls*) or (outpatient NEAR/3 therapy) or (outpatient NEAR/3 therapies) or (outpatient* NEAR/3 treatment*) or (outpatient* NEAR/3 tocoly*):ti,ab,kw | 6598
#26 | (long NEXT term NEXT therapy) or (long NEXT term NEXT therapies) or (long NEXT term NEXT therapeutic) or (long NEXT term NEXT treatment*) or (long NEXT term NEXT management) or (long NEXT term NEXT tocoly*) or (longterm NEXT therapy) or (longterm NEXT therapies) or (longterm NEXT therapeutic) or (longterm NEXT treatment*) or (longterm NEXT management) or (longterm NEXT tocoly*):ti,ab,kw | 3944
#27 | (#19 OR #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26) | 49538
#28 | (#15 AND #18 AND #27) | 51

51 records

DSR – 3

DARE – 1

CENTRAL – 41

HTA – 1

NHS EED – 5

CRD Databases – 2010 Jan 2

| Search | [underlined: Matching Records]
# 1 | [underlined: MeSH Obstetric Labor, Premature EXPLODE 1] | 146
# 2 | [underlined: PTL OR PTB OR RPT] | 13
# 3 | [underlined: ( premature* NEAR labor* ) OR ( premature* NEAR labour* ) OR ( premature* NEAR birth* ) OR ( premature* NEAR deliver* )] | 153
# 4 | [underlined: ( premature NEAR contract* )] | 11
# 5 | [underlined: ( pre NEAR mature* NEAR labor* ) OR ( pre NEAR mature* NEAR labour* ) OR ( pre NEAR mature* NEAR birth* ) OR ( pre NEAR mature* NEAR deliver* )] | 1
# 6 | [underlined: pre NEAR mature NEAR contract*] | 0
# 7 | [underlined: ( preterm NEAR labor* ) OR ( preterm NEAR labour* ) OR ( preterm NEAR birth* ) OR ( preterm NEAR deliver* )] | 342
# 8 | [underlined: preterm NEAR contract*] | 25
# 9 | [underlined: ( pre NEAR term NEAR labor* ) OR ( pre NEAR term NEAR labour* ) OR ( pre NEAR term NEAR birth* ) OR ( pre NEAR term NEAR deliver* )] | 97
# 10 | [underlined: ( pre NEAR term NEAR contract* )] | 7
# 11 | [underlined: ( early NEAR labor* ) OR ( early NEAR labour* ) OR ( early NEAR birth* ) OR ( early NEAR deliver* )] | 281
# 12 | [underlined: early NEAR contract*] | 28
# 13 | [underlined: MeSH Tocolysis EXPLODE 1] | 14
# 14 | [underlined: tocolysis OR tocolytic*] | 67
# 15 | [underlined: MeSH Terbutaline EXPLODE 1 2] | 17
# 16 | [underlined: Terbutalin* OR Brethaire OR Brethine OR Bricanyl OR “BRN 2370513” OR “EINECS 245-385-8” OR “UNII-N8ONU3L3PG”] | 37
# 17 | [underlined: #1 OR #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14] | 726
# 18 | [underlined: #15 OR #16] | 44
# 19 | [underlined: #17 AND #18] | 18
# 20 | [underlined: MeSH Injections, Subcutaneous EXPLODE 1] | 103
# 21 | [underlined: MeSH Infusion Pumps EXPLODE 1 2] | 89
# 22 | [underlined: MeSH Home Infusion Therapy EXPLODE 1 2] | 26
# 23 | [underlined: MeSH Infusions, Parenteral EXPLODE 1] | 359
# 24 | [underlined: subcutaneous* OR SubQ OR ( sub NEAR cutaneous* ) OR pump OR pumps OR infuse OR infused OR infuses OR infusing OR infusion* OR infuser*] | 1589
# 25 | [underlined: ( home NEAR therapy ) OR ( home NEAR therapies ) OR ( home NEAR tocoyl* )] | 280
# 26 | [underlined: (maintenance NEAR therapy) or (maintenance NEAR therapies) or (maintenance NEAR therapeutic) or (maintenance NEAR treatment*) or (maintenance NEAR tocoly*) or (supportive NEAR therapy) or (supportive NEAR therapies) or (supportive NEAR treatment*) or (supportive NEAR tocoyls*) or (outpatient NEAR therapy) or (outpatient NEAR therapies) or (outpatient* NEAR treatment*) or (outpatient* NEAR tocoly*)] | 0
# 27 | [underlined: ( maintenance NEAR therapy ) OR ( maintenance NEAR therapies ) OR ( maintenance NEAR therapeutic ) OR ( maintenance NEAR treatment* ) OR ( maintenance NEAR tocoly* )] | 707
# 28 | [underlined: ( supportive NEAR therapy ) OR ( supportive NEAR therapies ) OR ( supportive NEAR treatment* ) OR ( supportive NEAR tocoyls* )] | 350
# 29 | [underlined: ( outpatient NEAR therapy ) OR ( outpatient NEAR therapies ) OR ( outpatient* NEAR treatment* ) OR ( outpatient* NEAR tocoly* )] | 991
# 30 | [underlined: #20 OR #21 OR #22 OR #23 OR #24 OR #25 OR #26 OR #27 OR #28 OR #29] | 3794
# 31 | [underlined: #19 AND #30] | 14

14 records

DARE - 7

NHS EED - 6

HTA - 1