# Appendixes

Appendix A Search Strategies

Appendix B Grey Literature Search

Appendix C Scientific Information Packet Request

Appendix D Screening, Data Extraction, Risk of Bias, and Applicability Forms

Appendix E Excluded Studies

Appendix F Evidence Tables

Appendix G Modifications to Key Questions