# Acronyms and Abbreviations

AHRQ: Agency for Healthcare Research and Quality
BMI: Body mass index
BPD: Bronchopulmonary dysplasia
CI: Confidence interval
CRD: Centre for Reviews and Dissemination
FDA: Food and Drug Administration
GA: Gestational age
GTT: Glucose tolerance test
IVH: Intraventricular hemorrhage
NICU: Neonatal intensive care unit
OR: Odds ratio
PICOTS: Population, intervention, comparison, outcome, timing, setting
PTL: Preterm labor
RCT: Randomized controlled trial
RPTL: Recurrent preterm labor
SQ: Subcutaneous
SQT: Subcutaneous terbutaline
SRC: Scientific Resource Center
TEP: Technical expert panel
Withdrawal-AE: Withdrawal due to adverse effects