# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Jessica Dy, M.D. and Elizabeth Darling R.M., M.Sc. for their intellectual contributions to the topic refinement document of the review.