# Technical Expert Panel

Arnold Baas, M.D.

UCLA

Los Angeles, CA

Henry R. Black, M.D.

American Society of Hypertension

New York, NY

Carrie Gray, M.B.A., D.H.S.

Wisconsin Department of Health Services

Madison, WI

Julia B. Lewis, M.D.

Vanderbilt University

Nashville, TN

Eric Peterson, M.D.

Duke University

Durham, NC

John Spertus, M.D.

University of Missouri–Kansas City

Kansas City, MO

Til Sturmer, D.Phil., M.P.H.

University of North Carolina

Chapel Hill, NC

C. Michael White, Pharm.D.

University of Connecticut

Storrs, CT