# Summary and Discussion

A succinct summary of the results of this review of the comparative long-term benefits and harms of angiotensin-converting enzyme inhibitor(s) (ACEIs), angiotensin II receptor blocker(s)/antagonist(s) (ARBs), or direct renin inhibitors for adults with essential hypertension is provided in three tables. First, we give an aggregated view of the strength of evidence and brief conclusions (Table 27). Second, we further describe the nature and quality of the evidence (Table 28). Finally, we summarize the quantitative analyses of outcomes, offering an estimate of the comparative outcomes for ACEIs (Table 29).

Table 27 Summary of evidence on comparative long-term benefits and harms of ACEIs, ARBs, and direct renin inhibitors for essential hypertension

Key question | Strength of evidence | Conclusions
Key Question 1. For adult patients with essential hypertension, how do ACEIs, ARBs, and direct renin inhibitors differ in the following health outcomes:
a. Blood pressure control? | High (ACEI vs. ARB); Low (DRI vs. ACEI or ARB) | ACEIs and ARBs appear to have similar long-term effects on blood pressure among individuals with essential hypertension. This conclusion is based on evidence from 77 studies (70 RCTs, 5 nonrandomized controlled clinical trials, 1 retrospective cohort study, and 1 case-control study) in which 26,170 patients receiving an ACEI or an ARB were followed for periods from 12 weeks to 5 years (median 24 weeks). Blood pressure outcomes were confounded by additional treatments and varying dose escalation protocols. Evidence concerning the effect of direct renin inhibitors on blood pressure is very limited and currently based on only three studies. These studies found the direct renin inhibitor to have a greater reduction in blood pressure compared to the ACEI ramipril (two studies) and no significant difference compared to the ARB losartan (one study).
b. Mortality and major cardiovascular events? | Low (ACEI vs. ARB); Insufficient (DRI vs. ACEI or ARB) | Due to low numbers of deaths or major cardiovascular events reported, it was difficult to discern any differential effect of ACEIs versus ARBs versus direct renin inhibitors with any certainty for these critical outcomes. In 21 studies that reported mortality, MI, or clinical stroke as outcomes among 38,589 subjects, there were 38 deaths and 13 strokes reported. This may reflect low event rates among otherwise healthy patients and relatively few studies with extended followup. Only 3 of these 21 studies (including 1 death) evaluated direct renin inhibitors versus ACEIs or ARBs, and therefore the evidence to discern any differential effects between these drug classes on mortality and major cardiovascular events was insufficient.
c. Quality of life? | Low (ACEI vs. ARB); Insufficient (DRI vs. ACEI or ARB) | No differences were found between ACEIs and ARBs in measures of general quality of life; this is based on four studies, two of which did not provide quantitative data. No study evaluated the comparative effectiveness of direct renin inhibitors for quality-of-life outcomes.
d. Rate of use of a single antihypertensive medication? | High (ACEI vs. ARB); Insufficient (DRI vs. ACEI or ARB) | There was no statistically evident difference in the rate of treatment success based on use of a single antihypertensive for ARBs compared to ACEIs. The trend toward less frequent addition of a second agent to an ARB was heavily influenced by retrospective cohort studies, where medication discontinuation rates were higher in ACEI-treated patients, and by RCTs with very loosely defined protocols for medication titration and switching. There were no relevant studies evaluating direct renin inhibitors.
e. Risk factor reduction and other intermediate outcomes? | Lipid levels, markers of carbohydrate metabolism/ diabetes control, progression of renal disease: Moderate (ACEI vs. ARB); Insufficient (DRI vs. ACEI or ARB) Progression to type 2 diabetes and LV mass/function: Low (ACEI vs. ARB); Insufficient (DRI vs. ACEI or ARB) | There were no consistent differential effects of ACEIs, ARBs, on several potentially important clinical outcomes, including lipid levels and markers of carbohydrate metabolism/diabetes control. There appears to be a small difference in change in renal function between ACEIs and ARBs (favoring ACEIs), but this difference is both small and most likely not clinically meaningful or significant. Relatively few studies assessed these outcomes over the long term. There were no studies that evaluated these outcomes in direct renin inhibitors. There was no evidence for an impact of ACEIs, ARBs, or direct renin inhibitors on glucose or A1c, and no included studies evaluated rates of progression to type 2 diabetes mellitus. Although we included 13 studies of LV mass/function, these were dominated by poor-quality studies with small sample sizes, and only one study included evaluation of a direct renin inhibitor.
Key Question 2. For adult patients with essential hypertension, how do ACEIs, ARBs, and direct renin inhibitors differ in safety, adverse events, tolerability, persistence with drug therapy, and treatment adherence? | Cough: High (ACEI vs. ARB); Insufficient (DRI vs. ACEI or ARB) Withdrawals due to adverse events: High (ACEI vs. ARB); Low (DRI vs. ACEI or ARB) Angioedema: Low (ACEI vs. ARB); Insufficient (DRI vs. ACEI or ARB) Persistence with drug therapy/treatment adherence: Moderate (ACEI vs. ARB); Insufficient (DRI vs. ACEI or ARB) | ACEIs have been consistently shown to be associated with greater risk of cough than ARBs (odds ratio 0.211; 95% CI 0.159 to 0.281). For RCTs, this translates to a difference in rates of cough of 7.8 percent; however, for cohort studies with lower rates of cough, this translates to a difference of 1.2 percent. There were only two studies comparing direct renin inhibitors to ACEIs and these gave an estimated odds ratio of 0.333 (95% CI of 0.2241 to 0.4933). The withdrawal rate for ARBs was found to have an estimated odds ratio of 0.565 (95% CI 0.453 to 0.704) compared with ACEIs. For RCTs, this translated to an absolute difference in withdrawals of 2.3 percent (5.4% versus 3.1%). The direct renin inhibitor trials did not find a statistically significant difference (odds ratio 0.886; 95% CI 0.458 to 1.714) when compared with the withdrawal rate associated with ACEIs. There was no evidence of differences across treatments in rates of other commonly reported specific adverse events. Although several studies collected data on angioedema, the event rates were very low or zero for all studies; this limited our ability to accurately characterize the frequency of angioedema. In the four studies that did report episodes of angioedema, this adverse event was observed only in patients treated with an ACEI (five patients from three studies) or a direct renin inhibitor (one patient in one study). ACEIs and ARBs have similar rates of treatment adherence based on pill counts; this result may not be applicable outside the clinical trial setting. Rates of continuation with therapy appear to be somewhat better with ARBs than with ACEIs; however, due to variability in definitions, limitations inherent in longitudinal cohort studies, and relatively small sample sizes for ARBs, the precise magnitude of this effect is difficult to quantify. The three included studies evaluating direct renin inhibitors did not find evidence of differences in treatment adherence compared with ACEIs or ARBs. Persistence was not evaluated in any of the studies including direct renin inhibitors.
Key Question 3. Are there subgroups of patients – based on demographic and other characteristics (i.e., age, race, ethnicity, sex, comorbidities, concurrent use of other medications) – a for whom ACEIs, ARBs, or direct renin inhibitors are more effective, are associated with fewer adverse events, or are better tolerated? | Insufficient (ACEI vs. ARB; DRI vs. ACEI or ARB) | Evidence does not support conclusions regarding the comparative effectiveness, adverse events, or tolerability of ACEIs, ARBs, and direct renin inhibitors for any particular patient subgroup.

ACEI(s) = angiotensin-converting enzyme inhibitor(s); ARB(s) = angiotensin II receptor blocker(s)/antagonist(s); CI = confidence interval; GFR = glomerular filtration rate; LV = left ventricular; MI = myocardial infarction; RCTs = randomized controlled trials

Table 28 Quality of evidence summary table^*^

Studies | Design | Quality | Consistency | Directness | SD | SA | DR | PC
Outcome: Blood pressure control
70 | RCTs | Confounded by additional treatments, dose escalation | Consistent results | Direct | - | - | - | -
7 | 5 nonrandomized controlled trials, 1 cohort study, 1 case-control | Confounded by additional treatments, dose escalation | Consistent results | Direct | - | - | - | -
Outcome: Mortality and major cardiovascular events
17 | RCTs | No serious limitations | Consistent results | Direct | + | - | - | -
4 | 1 prospective observational study, 3 retrospective studies | Limitations based on study design | Consistent results | Direct | + | - | - | -
Outcome: Morbidity/quality of life
4 | RCTs | No serious limitations | Consistent results | Direct | - | - | - | -
Outcome: Safety (serious and overall adverse events, withdrawals due to adverse events)
12 – serious AEs 45 – overall AEs 39 – withdrawals due to AEs | RCTs | Variation in study protocols and data reporting | Consistent results | Direct | - | - | - | -
2 – overall AEs 2 – withdrawals due to AEs | 1 nonrandomized controlled trial; 1 case-control | Limitations based on study design | Consistent results | Direct | + | - | - | -
Outcome: Specific adverse events
45 | RCTs | Variation in data reporting | Consistent results | Direct | - | - | - | -
3 | 3 cohort studies | Limitations based on study design | Consistent results | Direct | + | - | - | -
Outcome: Persistence with drug therapy/treatment adherence
26 | RCTs | Variation in data reporting | Consistent results | Direct | - | - | - | -
13 | 13 cohort studies | Limitations based on study design | Consistent results | Direct | - | - | - | -
Outcome: Rate of use of a single agent for blood pressure control
23 | RCTs | No serious flaws | Consistent results | Direct | - | - | - | -
3 | 2 cohort studies, 1 case-control | Limitations based on study design | Consistent results | Direct | + | - | - | -
Outcome: Lipid levels
18 | RCTs | No serious flaws | Inconsistent results between studies and between lipid parameters | Direct | - | - | - | -
2 | 1 nonrandomized clinical trial, 1 case-control | Limitations based on study design | Inconsistent results between studies and between lipid parameters | Direct | + | - | - | -
Outcome: Rates of progression to type 2 diabetes
0 | NA | NA | NA | NA | + | - | - | -
Outcome: Markers of carbohydrate metabolism/diabetes control
18 | RCTs | No serious flaws | Inconsistent results between head-to-head studies and placebo-controlled studies | Direct | - | - | - | -
5 | 2 nonrandomized controlled trials, 1 case-control, 1 prospective observational study, 1 retrospective chart review | Limitations based on study design | Consistent results | Direct | + | - | - | -
Outcome: Measures of LV mass/function
11 | RCTs | Poor quality studies; small sample sizes | Consistent results | Direct | - | - | - | -
2 | 1 nonrandomized controlled trial; 1 case-control | Poor quality studies; small sample sizes | Consistent results | Direct | + | - | - | -
Outcome: Measures of kidney disease
21 – GFR 16 – proteinuria | RCTs | Poor quality studies; different parameters measured | Consistent results | Direct | - | - | - | -
21 – GFR 16 – proteinuria | RCTs | Poor quality studies; different parameters measured | Inconsistent results | Direct | - | - | - | -
3 – GFR 1 – proteinuria 1 – both | 1 nonrandomized controlled trial, 2 cohort studies, 1 case-control, 1 prospective observational study | Limitations based on study design | Consistent results | Direct | + | - | - | -

* Table legend:

Consistency: This column indicates whether the included studies had inconsistent results or if there is evidence of a dose response or that adjustment for confounders would have increased the effect size.

Directness: This column refers to issues that may limit the generalizability of the reported results to our specified population of interest. Such issues may include, for example, a restricted population in trials, the inclusion of too broad a population in trials, or the use of co-interventions in addition to our intervention of interest.

AEs = adverse events; DR = dose response; GFR = glomerular filtration rate; LV = left ventricular; PC = all plausible confounders would reduce the effect; RCT(s) = randomized controlled trial(s); SA = strong association (+ = very strong, ++ = extremely strong); SD= sparse data; - = no relevant data

Table 29 GRADE balance sheet

Outcome | Number of patients treated with ACEIs, ARBs, or direct renin inhibitors and assessed for outcome of interest | | | Effect based on meta-analysis | Quality | Relative importance
Outcome
Outcome | ACEI | ARB | Direct renin inhibitor | Effect (95% CI)
BP reduction | ~ 13,600 | ~ 13,600 | 1104 | - | High | Critical
Rate of use of a single antihypertensive for BP control | ~12,840 | ~12,840 | No data | Estimated odds ratio of ARBs vs. ACEIs 1.083 (95% CI 0.937 to 1.252) | High
Mortality and major CV events | ~18,700 | ~18,700 | 1104 | - | Moderate | Critical
Morbidity/Quality of life | ~ 550 | ~ 550 | | No difference detected | Low | -
Cough | 45,441 | 22,437 | 877 | Estimated odds ratio of ARBs vs. ACEIs 0.212 210 (95% CI 0.158 to 0.279) | High
Cough | 45,441 | 22,437 | 877 | Estimated odds ratio of direct renin inhibitors vs. ACEIs 0.333 (95% CI 0.2241 to 0.4933) | Low
Adverse events – withdrawals | 4744 | 4935 | 877 | Estimated odds ratio of ARBs vs. ACEIs 0.565 (95% CI 0.453 to 0.704) Estimated odds ratio of direct renin inhibitors vs. ACEIs 0.886 (95% CI 0.458 to 1.714) | High | Critical
Persistence/ adherence | 158,571 | 157,706 | 877 | - | Moderate
Lipid levels | 5112 | 5278 | No data | - | Moderate | -
Progression to type 2 diabetes | No data | No data | No data | - | Low | -
Markers of carbohydrate metabolism/diabetes control | 5042 | 5191 | No data | - | Moderate | -
Measures of LV mass/function | ~777 | ~545 | ~233 | - | Low | -
Measures of kidney disease – creatinine/GFR | 1004 | 483 | 457 | Serum creatinine: Standardized mean difference of ARBs vs. ACEIs 0.109 (95% CI -0.054 to 0.272) Creatinine clearance: Standardized mean difference of ARBs vs. ACEIs -0.217 (95% CI -0.515 to 0.080) GFR: Standardized mean difference of ARBs vs. ACEIs -0.227 (95% CI -0.486 to 0.032) All flow studies: Standardized mean difference of ARBs vs. ACEIs -0.227 (95% CI -0.396 to -0.028) | Moderate | -
Measures of kidney disease – proteinuria | 334 | 242 | 73 | - | Low | -

BP = blood pressure; CI = confidence interval; CV = cardiovascular; GFR = glomerular filtration rate; LV = left ventricular; - = no relevant data