# Results

## Literature Search and Screening

Our searches of the literature identified a total of 2,090 citations. Table 3 details the number of citations identified from each source.

Table 3 Sources of citations

Source | Number of citations
MEDLINE | 1,428
Embase | 355
Cochrane Central Register of Controlled Trials | 45
Register of systematic reviews underway in the Cochrane Hypertension Group | 0
References of review articles and primary studies | 27
Scientific information packets submitted by pharmaceutical companies | 17
Other (recommendations from staff at AHRQ or SRC or from project investigators) | 218
Total: | 2,090

Figure 2 describes the flow of literature through the screening process. Of the 2,090 citations identified by our searches, 1083 were excluded at the abstract screening stage. Of the 1,007 citations that passed the abstract screening, 276 were review or methods articles, 403 were indirect comparator studies identified for our original report (see Appendix B), and 328 were direct comparator studies of angiotensin-converting enzyme inhibitors (ACEIs), angiotensin II receptor blocker(s)/antagonist(s) (ARBs), and direct renin inhibitors. The remainder of this section describes results for the direct comparator studies.

Figure 2 Literature flow diagram

Figure 2 describes the flow of literature through the screening process. Of the 2,090 citations identified by our searches, 1,083 were excluded at the abstract screening stage. Of the 1,007 citations that passed the abstract screening, 276 were review or methods articles, 403 were indirect comparator studies identified for our original report, and 328 were direct comparator studies of ACEIs, ARBs, and direct renin inhibitors. At the full-text screening stage, 217 of the 328 direct comparator studies were excluded, leaving a total of 111 included articles.

At the full-text screening stage, 218 of the 328 direct comparator studies were excluded for the reasons summarized in Figure 2, leaving a total of 110 included articles. Appendix G provides a complete list of articles excluded at the full-text screening stage, with reasons for exclusion.

The 110 included direct comparator articles reported on 100 distinct studies. Seventy-four of these were randomized controlled trials (RCTs), 4 were nonrandomized controlled trials, 16 were retrospective cohort studies, 3 were prospective cohort studies, and 1 study each was a cross-sectional cohort, a case-control study, and a retrospective chart review. Table 4 describes the number of studies that evaluated various possible treatment comparisons.

Table 4 Number of studies (number of publications) that evaluated various treatment comparisons^*^

| | ARBs | | | | | | | | DRI | Totals
| | Unspecified “ARBs” | Candesartan cilexetil | Eprosartan | Irbesartan | Losartan | Olmesartan medoxomil | Telmisartan | Valsartan | Aliskiren | Totals
ACEIs | Unspecified “ACEIs” | 21 (24) | 0 | 0 | 2 (2) | 2 (1) | 0 | 0 | 0 | 0 | 24 (27)
ACEIs | Benazepril | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 (1) | 0 | 1 (1)
ACEIs | Captopril | 0 | 0 | 0 | 0 | 2 (2) | 0 | 0 | 0 | 0 | 2 (2)
ACEIs | Enalapril | 0 | 4 (4) | 2 (6) | 4 (4) | 14 (15) | 0 | 5 (5) | 2 (2) | 0 | 31 (36)
ACEIs | Fosinopril | 0 | 0 | 0 | 2 (2) | 1 (1) | 0 | 0 | 0 | 0 | 3 (3)
ACEIs | Lisinopril | 0 | 6 (6) | 0 | 0 | 1 (1) | 0 | 3 (3) | 5 (5) | 0 | 15 (15)
ACEIs | Moexipril | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0
ACEIs | Perindopril | 0 | 1 (1) | 0 | 0 | 3 (3) | 0 | 3 (3) | 0 | 0 | 7 (7)
ACEIs | Quinapril | 0 | 0 | 0 | 2 (2) | 3 (3) | 0 | 0 | 0 | 0 | 5 (5)
ACEIs | Ramipril | 0 | 0 | 0 | 0 | 2 (2) | 1 (1) | 5 (5) | 3 (3) | 2 (3) | 13 (14)
ACEIs | Trandolapril | 0 | 0 | 0 | 0 | 1 (1) | 0 | 0 | 0 | 0 | 1 (1)
DRI | Aliskiren | 0 | 0 | 0 | 0 | 1 (1) | 0 | 0 | 0 | - | 1 (1)
| Totals | 21 (24) | 11 (11) | 2 (6) | 10 (10) | 29 (30) | 0 | 16 (16) | 11 (11) | 2 (3) | -

* Total exceed 100 studies/110 publications because some trials reported on more than one ACE-inhibitors vs. ARB treatment comparison.

As Table 4 illustrates, enalapril was by far the most frequently studied ACEI (31 studies) and losartan the most frequently studied ARB (29 studies), followed by telmisartan (16 studies). The most commonly studied treatment comparison was the generic “ACEIs” versus “ARBs” (21 studies), followed by enalapril versus losartan (14 studies). Other treatment comparisons were fairly sparsely represented.

In terms of quality, 54 studies were rated as fair, 30 as poor, and 16 as good. The distribution of studies by followup time is given in Table 5.

Table 5 Distribution of studies by followup time

Treatment duration/followup time | Report studies
12 weeks | 23
14–16 weeks/3–4 months | 15
22 weeks | 1
24–26 weeks/6 months | 22
30 weeks | 1
36 weeks | 2
10–11 months | 2
48 weeks | 4
1 year | 16
15 months | 1
1.8 years | 1
720 days | 1
2 years | 1
33 months | 1
3 years | 4
39 months | 1
4 years | 2
5 years | 1
~ 70 months | 1

There was no obvious correlation between study quality and length of followup. The 16 good-quality studies varied in length from 12 weeks (3 studies), 13 to 36 weeks (7 studies), 1 year (4 studies), to 2 years (2 studies).

## Key Question 1 For adult patients with essential hypertension, how do ACEIs, ARBs, and direct renin inhibitors differ in blood pressure control, cardiovascular risk reduction, cardiovascular events, quality of life, and other outcomes?

### Key Points

- There was no clear difference in blood pressure lowering efficacy between ACEIs and ARBs. Data concerning direct renin inhibitors were limited.
- Few deaths or major cardiovascular events occurred in the identified studies comparing ACEIs, ARBs, and direct renin inhibitors; this significantly limited any assessment of a differential effect of these drug classes on these events.
- No significant difference was observed between ACEIs and ARBs in terms of their impact on quality of life. No evidence was available regarding the impact of direct renin inhibitors on quality of life.
- There was no statistically evident difference in rate of treatment success based on use of a single antihypertensive medication for ARBs compared to ACEIs. No evidence regarding the effect of direct renin inhibitors on this outcome was identified.
- Available evidence suggests that ACEIs and ARBs have a similar lack of impact on lipid levels for individuals with essential hypertension. No evidence regarding the effect of direct renin inhibitors on these outcomes was available.
- Available evidence suggests that ACEIs and ARBs have a similar lack of impact on glucose levels or HbA1c for individuals with essential hypertension. No evidence regarding the effect of direct renin inhibitors on these outcomes was available.
- Evidence does not demonstrate a difference between ACEIs, ARBs, and direct renin inhibitors with regard to their effect on left ventricular (LV) mass or function for individuals with essential hypertension.
- There are no consistently demonstrated differential effects related to renal function as measured by creatinine or glomerular filtration rate (GFR) with use of ACEIs, ARBs, or direct renin inhibitors. There appears to be a small difference in change in renal function favoring ACEIs over ARBs, but the clinical significance of these small effects is uncertain.
- There is a consistent finding of no differential effect related to reduction of urinary protein or albumin excretion among patients with essential hypertension with use of ACEIs, ARBs, or direct renin inhibitors.

### Effect on Blood Pressure

#### Comparisons of ACEIs Versus ARBs

Seventy-seven studies described in 83 separate publications met our inclusion criteria and reported a blood pressure outcome. Of these, 12 (16 percent) were of good methodological quality,23-34 42 (55 percent; 47 papers) were of fair quality,35-78 and 23 (30 percent) were of poor quality.79-102 There were 5 nonrandomized controlled clinical trials,80,83,84,89,96 1 retrospective cohort study,49 and 1 case-control study;99 the remaining 70 studies were RCTs. Sample sizes for individual studies ranged from 24 patients to 3,813 patients, and a total of 26,170 patients received an ACEI or an ARB. Study durations ranged from 12 weeks to 5 years, with a median of 24 weeks.

The mean age of study participants ranged from 33 years old to 73 years old, with a median of 55.4 years old. The proportion of female patients included ranged from 19 percent to 100 percent, with a median of 48 percent. Only 33 studies (43 percent; 39 papers) reported the racial demographics of the study participants.25,26,29,30,32-40,43,48,52-56,58,61,63,64,69,71,75-77,80,91,92,97,103-108 Of these 33 studies, only 12 (36 percent; 17 papers) enrolled a minimum of 10 percent of ethnic minority participants.29,36,38,39,43,48,52,54-56,61,63,76,97,103,104,106

Seven studies (9 percent) were conducted entirely within the United States or Canada,29,38,52,53,63,76,106 with the remainder carried out in other countries. The funding source was reported in 44 studies (57 percent; 49 papers),25-33,36-40,42,43,48-50,52-62,65-67,69-71,74,78-80,83,92-95,97-99,109 with the majority of these (29 studies) funded by the manufacturer of one of the study medications.

The mean systolic blood pressure (SBP) and diastolic blood pressure (DBP) at the beginning of each study ranged from 127 to 199 mm Hg and 67 to 119 mm Hg, respectively, with a mean starting blood pressure of 156/97 mm Hg. There was significant heterogeneity in the study protocols and data reporting. Fewer than half of the studies (30/77; 39 percent; 31 papers) did not allow additional hypertension medications during the study;23,25,27,35,38,40,41,44,45,47,56-59,64-66,69,72,74,75,77,80,83,85,87,91,92,102,106,108 29 studies (38 percent; 33 papers) allowed additional medications according to a specified protocol;26,28,29,31-34,36,39,43,48,50-55,61,63,67,68,70,71,73,76,78,82,86,88,98-100,109 6 studies (8 percent; 7 papers) allowed additional medications at the discretion of the treating physician;30,37,49,60,62,94,95 and 12 studies (16 percent) did not report concomitant hypertension therapy.24,42,46,79,81,84,89,90,93,96,97,101 The reported blood pressure endpoints varied as well, with 51 studies (66 percent; 53 papers) reporting the difference in final post-treatment blood pressure;25,26,29,31-34,40-42,44-47,50,53,56,58,61-68,70,71,74,75,77-83,86-88,90-99,101,102,106 35 studies (45 percent; 40 papers) reporting the mean change in blood pressure in each study arm;23,24,26-30,35-40,43-46,48,49,51,52,54-58,60,61,63,64,69,73,75,76,84,85,91,100,106,108 and 4 studies (5 percent) not providing quantitative data for the blood pressure outcome or reporting only the proportion of patients achieving a target blood pressure.59,72,89,109

For the overall comparison of blood pressure lowering between ACEIs and ARBs, 57 studies reported no difference (74 percent; 62 papers),23,24,26,28,30-34,36-44,46,48,50-55,58-63,65-67,70-74,76-82,86-90,92-101,109 2 studies favored ACEIs (3 percent; 3 papers),29,64,75 11 studies favored ARBs (14 percent),25,27,35,45,47,56,57,69,91,106,108 and 6 studies (8 percent) did not report the comparison between the two agents.49,68,83-85,102 We did not detect any specific ACEI or ARB that performed better or worse than other medications in its class.

Blood pressure outcomes were confounded by protocols calling for dose escalation or adding additional blood pressure-lowering drugs; such protocols differed substantially between studies, making the blood pressure outcomes difficult to interpret. Overall, there was no clear difference in the blood pressure lowering efficacy between the two classes of agents, no matter what criteria were used for study inclusion. Because of the heterogeneity in study protocols, quantitative meta-analysis was not performed. However, despite some differences in methods for measuring successful control of blood pressure on a single agent, this outcome seemed to represent a reasonable comparison that was not confounded by substantial differences between studies. Therefore, quantitative meta-analysis was performed for this outcome.

Caveats and concerns include the fact that there was significant heterogeneity in the medication protocols and the use of concomitant hypertension therapy. Many of the studies reported limited data on patient characteristics, and black patients appeared to be significantly underrepresented overall. Very few of the studies were considered to be of good methodological quality. In addition, the majority of the studies reporting a funding source were sponsored by the manufacturer of the ARB.

#### Comparisons of Direct Renin Inhibitors Versus ACEIs or ARBs

We identified three studies (four publications) comparing the direct renin inhibitor aliskiren with either an ACEI or ARB.103-105,107 All three studies were good-quality RCTs. Two compared the ACEI ramipril at a maximum dose of 10 mg to aliskiren at a maximum dose of 300 mg and used a similar protocol that allowed additional medications to be added if the blood pressure was above target at 12 weeks. In both studies, aliskiren produced a greater reduction in blood pressure compared to ramipril at 12 weeks, with between-group blood pressure (SBP/DBP) differences of -2.7/-1.6^103,104^ and -2.3/-1.5 mmHg.105 The third study compared aliskiren to the ARB losartan and reported no significant differences in blood pressure lowering or in use of single antihypertensive agent.107

#### Effect on Mortality and Major Cardiovascular Events

The literature review identified 26 publications25,26,28,30,32,36,37,39,43,48,52,53,55,74,88,98,101,103-105,107,108,110-113 describing 21 separate studies that reported patient mortality, myocardial infarction (MI), or clinical stroke as outcomes. Seventeen studies (22 publications) were RCTs.25,26,28,30,32,36,37,39,43,48,52,53,55,74,88,98,101,103-105,107,108 The 21 studies reported on 40,749 patients (38,589 of whom received an ACEI, an ARB, or a DRI) and ranged in duration from 12 weeks to 5 years; most reported blood pressure measurements as primary endpoints. The treatment comparisons evaluated were (one study per comparison, unless otherwise noted):

- “ACEIs” versus “ARBs” (3 studies);110,112,113
- Candesartan versus lisinopril;32
- Eprosartan versus enalapril (2 studies, 6 publications);30,36,39,43,48,55
- Losartan versus enalapril (2 studies);53,74
- Losartan versus fosinopril;88
- Losartan versus ramipril;98
- Losartan versus quinapirl;52
- Telmisartan versus ramipril;108
- Telmisartan versus enalapril (2 studies);37,101
- Valsartan versus lisinopril (3 studies);26,28,111
- Valsartan versus enalapril;25
- Aliskiren versus ramipril (2 studies, 3 publications);103-105 and
- Aliskiren versus losartan.107

The studies were of good (n = 8), fair (n = 9), and poor (n = 4) quality. Notably, the majority of studies in this review—including those reporting mortality and major cardiovascular events—excluded patients with significant cardiovascular disease and often other comorbid conditions.

The studies evaluated shed little light on the issue of relative rates of mortality, MI, or stroke with ACEIs versus ARBs versus direct renin inhibitors. In 21 studies involving 40,749 patients, 38 patients died. The study by Barnett et al.37 provided the most and the longest-term data on cardiovascular events. This study evaluated telmisartan versus enalapril in 250 patients with type 2 diabetes and early nephropathy over a 5-year treatment period. In this higher risk population, cardiovascular events occurred at a similar rate in both treatment groups: there were six strokes in each group; nine nonfatal MIs in the telmisartan group and six in the enalapril group; and nine patients with heart failure in the telmisartan group and six in the enalapril group. This study also reported 12 deaths, 6 in the telmisartan group (3 due to stroke, MI, and heart failure), and 6 in the enalapril group (2 due to MI).

Among shorter-term trials, the study by Ruilope et al.,30 evaluating eprosartan versus enalapril over 12 weeks, reported one death in each group, a 95-year-old patient with cancer and an 80-year-old patient with heart failure. Shibaskaki et al.74 evaluated losartan versus enalapril versus amlodipine over 6 months and reported one death due to pulmonary hemorrhage, and one patient with MI; the treatment group to which the patient belonged was not specified for either event. The paper by Elliott et al.43 is the primary report of a trial of eprosartan versus enalapril over 26 weeks. A substudy from this trial published by Gavras et al.48 reported that one patient assigned to the eprosartan group had an anteroseptal MI and died. Williams et al.108 evaluated telmisartan versus ramipril over 14 weeks and reported that one patient in the ramipril group had a stroke. An RCT by Andersen et al.103,104 comparing aliskiren to ramipril noted one death due to mesenteric thrombosis in the ramipril group. An RCT comparing valsartan, lisinopril, or their combination noted one death in the lisinopril group and one in the combination group.28 Delea et al.111 performed a retrospective cohort study using administrative data and found cardiovascular event rates to be similar between patients taking valsartan versus lisinopril after adjusting for possible confounding characteristics. Finally, Spinar et al.98 described two studies in one publication: one a single-arm trial of losartan (n = 4,016), and the other an RCT of losartan versus ramipril (n = 3,813). The single-arm study reported a mortality rate of 0.1 percent over 1 year, with MI occurring in 0.2 percent of participants and stroke in 0.3 percent of participants. In the RCT, the rates of both mortality and MI were 0.2 percent, and the stroke rate was 0.4 to 0.5 percent in both treatment groups. In none of these trials did investigators attribute any of the events observed directly to therapy.

#### Effect on Quality of Life

Four studies described in eight separate papers reported data on quality of life.36,39,41,43,48,51,55,57 All four were RCTs comparing ACEIs versus ARBs, and all were rated as fair in methodological quality. However, with regard to assessing quality of life, two of the four could be considered poor, as they did not present quantitative data.51,57

Sample sizes for the individual studies ranged from 42 to 528 patients, with a total of 1,142 patients. Study durations ranged from 12 weeks to 3 years, with a mean of 55 weeks (median 26 weeks). Only one of the four studies reported the racial demographics of the study participants;43 in that study, 14 percent of participants were members of ethnic minorities. Studies utilized a variety of quality-of-life scales: two administered the Psychological General Well Being with its six subscales;43,57 two administered the Subjective Symptoms Assessment profile;41,43 one study employed the McMaster Overall Treatment Evaluation Questionnaire;57 and one used the Medical Outcomes Study 36-Item Short Form Health Survey (SF-36).51 Only two studies presented any quantitative data to support their conclusions of no difference in the impact of ACEIs or ARBs on quality of life.41,43

None of the studies found any difference between ACEIs and ARBs in their impact on the quality of life of study participants; indeed, no study demonstrated an impact on quality of life for subjects treated with ACEIs or ARBs. Finally, none of the studies comparing direct renin inhibitors with ACEIs or ARBs reported data on quality of life.

#### Effect on Rate of Use of a Single Antihypertensive Agent

We identified 26 studies that reported the outcome of successful monotherapy for ACEIs versus ARBs.26-30,34,36,45,49-54,60,63,68,70,71,76,77,82,86,88,99,109,114 The definition of “successful” monotherapy differed between studies and included SBP or DBP below a specified cutoff, or monotherapy defined by a lack of additional antihypertensive medication at the end of the study. Six studies were determined to be of good quality, 17 were fair in quality, and 4 were poor. There were 24 RCTs, 2 retrospective cohorts, and 1 case-control study. Sample sizes ranged from 30 patients to 13,303 patients. Study durations ranged from 12 weeks to 3.3 years, with a median of 26 weeks. The rates of successful monotherapy ranged between 6 percent and 93.3 percent (median 55 percent).

We performed a meta-analysis of data from the 26 studies. Individual study estimates for the differences between ACEIs and ARBs in the proportion of patients achieving successful blood pressure control on a single agent showed no statistical heterogeneity (Q = 36.6; df = 25; p = 0.063). A summary estimate of the odds ratio for the proportion of patients with successful blood pressure control on a single agent with ARBs compared to ACEIs was 1.128 (95% CI 1.002 to 1.270; p = 0.047; random-effects model).

Table 6 summarizes the studies and their estimated odds ratios. The odds ratio represents the odds of successful blood pressure control for ARB patients divided by the odds of successful blood pressure control for ACEI patients.

Table 6 Estimated odds ratios for successful blood pressure control on monotherapy (ARBs vs. ACEIs)

Study | Odds ratio | Ln(OR) | Standard error | Study type
Verdecchia et al., 2000^99^ | 1.2750 | 0.2429 | 0.4940 | OBS
Hasford et al., 2002^49^ | 1.5088 | 0.4113 | 0.1328 | OBS
Mazzaglia et al., 2005^114^ | 1.1083 | 0.1028 | 0.0711 | OBS
Townsend et al., 1995^76^ | 0.7873 | -0.2391 | 0.2448 | RCT
Ruff et al., 1996^29^ | 0.3351 | -1.0933 | 0.8076 | RCT
Larochelle et al., 1997^54^ | 1.4250 | 0.3542 | 0.6063 | RCT
Argenziano et al., 1999^36^ | 1.0000 | 0.0000 | 0.1881 | RCT
Karlberg et al., 1999^51^ | 1.0316 | 0.0311 | 0.2494 | RCT
Neutel et al., 1999^63^ | 0.8413 | -0.1728 | 0.1769 | RCT
Lacourciere et al., 2000^53^ | 0.4375 | -0.8267 | 0.4027 | RCT
Mogensen et al., 2000^60^ | 1.7609 | 0.5658 | 0.4233 | RCT
Ruilope et al., 2001^30^ | 0.7382 | -0.3036 | 0.4131 | RCT
Cuspidi et al., 2002^109^ | 1.0048 | 0.0048 | 0.2597 | RCT
Kavgaci et al., 2002^88^ | 0.7959 | -0.2283 | 0.8342 | RCT
Eguchi et al., 2003^82^ | 0.8750 | -0.1335 | 0.5804 | RCT
Ghiadoni et al., 2003^86^ | 1.2778 | 0.2451 | 0.6329 | RCT
Fogari et al., 2004^45^ | 1.3846 | 0.3254 | 0.3301 | RCT
Malacco et al., 2004^26^ | 1.0400 | 0.0392 | 0.1410 | RCT
Robles et al., 2004^68^ | 0.7273 | -0.3185 | 0.8006 | RCT
Saito et al., 2004^71^ | 1.5742 | 0.4537 | 0.2199 | RCT
Rosei et al., 2005^70^ | 0.8306 | -0.1857 | 0.3622 | RCT
Uchiyama-Tanaka et al., 2005^77^ | 1.1053 | 0.1001 | 0.7353 | RCT
Tedesco et al., 2006^34^ | 0.9240 | -0.0791 | 0.3036 | RCT
Hosohata et al., 2007^50^ | 1.9360 | 0.6606 | 0.1920 | RCT
Menne et al., 2008^28^ | 0.9974 | -0.0026 | 0.4838 | RCT
Malacco et al, 2010^27^ | 1.4069 | 0.3414 | 0.1216 | RCT

Ln(OR) = natural log of odds ratio; OBS = observational study; RCT = randomized controlled trial

We summarized all studies together and also analyzed RCTs and observational studies separately. Results for both fixed-effect and random-effects analyses are given in Table 7. The analyses include measures of homogeneity (Q-statistic). Results of an analysis of the potential for publication bias are provided in Appendix H.

Table 7 Meta-analyses of successful blood pressure control on monotherapy by subgroup for ARBs versus ACEIs

Model | Analysis subgroup | No. of studies | OR estimate | 95% CI lower limit | 95% CI upper limit | Z value | P value | Q value | df (Q) | P value
Fixed | All | 26 | 1.151 | 1.062 | 1.247 | 3.437 | 0.001 | 36.566 | 25 | 0.063
Random | All | 26 | 1.128 | 1.002 | 1.270 | 1.986 | 0.047
Fixed | Observ | 3 | 1.188 | 1.052 | 1.342 | 2.776 | 0.006 | 4.214 | 2 | 0.122
Random | Observ | 3 | 1.258 | 0.984 | 1.610 | 1.829 | 0.067
Fixed | RCTs | 23 | 1.123 | 1.010 | 1.250 | 2.138 | 0.033 | 31.887 | 22 | 0.079
Random | RCTs | 23 | 1.083 | 0.937 | 1.252 | 1.076 | 0.282

CI = confidence interval; df = degrees of freedom; Observ = observational studies; OR = odds ratio; RCTs = randomized controlled trials

Because the definition of successful control of blood pressure with a single agent requires that a patient remain on the originally prescribed drug and receive no additional antihypertensive agent, “successful monotherapy” reflects both the efficacy of the medication and tolerability and adherence to the prescribed therapy. When we examined our results separately for observational and experimental studies, the trend favoring ARBs for this outcome appeared to be driven primarily by differences in tolerability and adherence, since the benefit of ARBs appeared different in retrospective cohort studies, where medication discontinuation rates were higher in ACEI-treated patients.

The results for the random-effects analysis of RCTs alone are shown in Figure 3.

Figure 3 Random-effects analysis of RCTs for successful blood pressure control on monotherapy (ARBs vs. ACEIs)

Figure 3 displays a forest plot of RCTs reporting the odds ratio of successful blood pressure control on monotherapy, ARBs versus ACEIs. In the 23 studies the combined estimated odds ratio was 1.083 (95 percent CI 0.937 to 1.252), suggesting that the odds of successful blood pressure control is only 8 percent larger with an ARB alone than with an ACEI alone, and this amount is not statistically significant.

The results for this outcome are best summarized by the random-effects analysis of the RCTs shown in Figure 3. This analysis gave an estimated odds ratio of 1.083 (95 percent CI 0.937 to 1.252), suggesting that the odds of successful blood pressure control is only 8 percent larger with an ARB alone than with an ACEI alone, and this amount is not statistically significant.

These odds ratios need to be compared against the overall successful blood pressure control rate for monotherapy with ACEIs. If we pool all of the RCTs, we get a rate of about 54.7 percent.

The results for the random-effects analysis of the observational studies alone are shown in Figure 4.

Figure 4 Random-effects analysis of observational studies for successful blood pressure control on monotherapy (ARBs vs. ACEIs)

Figure 4 displays a forest plot of observational studies reporting the odds ratio of successful blood pressure control on monotherapy, ARBs versus ACEIs. In the three studies the combined estimated odds ratio was 1.258 (95% CI 0.984 to 1.610), suggesting that the odds of successful blood pressure control is 26 percent larger with an ARB alone than with an ACEI alone, and this amount is marginally statistically significant (p = 0.0673).

This analysis gave an estimated odds ratio of 1.258 (95% CI 0.984 to 1.610), suggesting that the odds of successful blood pressure control is 26 percent larger with an ARB alone than with an ACEI alone, and this amount is marginally statistically significant (p = 0.0673).

These odds ratios need to be compared against the overall successful blood pressure control rate for monotherapy with ACEIs. If we pool all of the observational studies, we get a rate of about 24.9 percent. While the magnitude of relative increase in successful monotherapy with ARBs represents a clinically important difference, this result should be interpreted with caution. The lack of concordance between pooled results in RCTs and observational studies suggests selection bias and residual confounding as potential explanations for this observed difference, rather than the inherent efficacy of the medication.

We did not identify any studies comparing a direct renin inhibitor with an ACEI or an ARB for this outcome.

#### Effect on Serum Lipid Levels

Twenty studies described in 25 papers met our inclusion criteria and evaluated serum lipid changes. Seventeen of the 20 studies were RCTs,23,25,32,34,43,44,46,53,62,70,73,75,77,86,88,101,102 1 was a nonrandomized three-arm parallel-group clinical trial,96 and 1 was an observational case-control study.99 One publication98 reported results from two studies: an RCT and a single-arm clinical trial of an ARB with an ACEI as a preintervention comparison (participants were switched from an ACEI to losartan). The ACEI-versus-ARB treatment comparisons were unique in 14 studies; 4 studies compared losartan versus enalapril,34,53,75,99 2 compared telmisartan versus perindopril,62,86 and 2 compared telmisartan versus enalapril.37,101 Study periods ranged from 3 to 24 months, all of which were sufficiently long to detect measurable changes in the lipid profile.

Most of the 20 studies were fair in quality, and none addressed the use of lipid-lowering agents during the study period. The four studies rated as good in quality23,25,32,34 took place in Europe and were moderate to large in sample size (range 70 to 520); one study was of short duration (16 weeks);25 two were of medium duration (12 months);23,32 and one was long (24 months).34 Two of the good-quality studies targeted patients with diabetes.23,32

The majority of the available head-to-head evidence suggests that ACEIs and ARBs have a similar lack of impact on lipid parameters. Twelve studies found no within-group change during treatment in total cholesterol (TC), low-density lipoprotein (LDL), high-density lipoprotein (HDL), and/or triglyceride (TG) levels during the study period. Four studies found statistically significant within-group treatment effects but did not report between-group comparisons (Table 8): TC and TG decreased with fosinopril, while TG decreased with losartan in one study;88 TC decreased with losartan in another study;34 TC decreased with losartan and enalapril, LDL decreased with losartan, and TG decreased with enalapril in a third study;53 and TC, TG, and LDL decreased, while HDL increased, with both ramipril and valsartan in the fourth study.102

Table 8 Studies reporting significant changes in lipid profiles with ACEIs and/or ARBs

Study | N | Population | Quality | Comparators | ΔTC | ΔLDL | ΔHDL | ΔTG
Lacourciere et al., 2000^53^ | 103 | - Mean age 58; - 96% white; - Canada; - Diabetes | Fair | Losartan vs. enalapril | -2.1%^*^ vs. -4.2%^*^ | -6.5%^*^ vs. NR | NR | NR vs. -11.3%^*^
Derosa et al., 2003^23^ | 96 | - Mean age 54; - Europe; - Diabetes | Good | Candesartan vs. perindopril | -1 mg/dL vs. -12 mg/dL^*,†^ | -4 mg/dL vs. -14 mg/dL^†^ | +2 mg/dL vs. -2 mg/DL | +2 mg/dL vs. -22 mg/dL
Kavgaci et al., 2002^88^ | 33 | - Mean age 53; - 100% white; - Turkey; - Diabetes | Poor | Losartan vs. fosinopril | +0.01% vs. -0.1%^*^ | NR | NR | -0.23%^*^ vs. -0.21%^*^
Tedesco et al., 2006^34^ | 520 | - Mean age 54; - 100% white; - Italy; - No diabetes | Good | Losartan vs. enalapril | -10 mg/dL^*^ vs. +1 mg/dL | NR | NR | NR
Yilmaz et al., 2007^102^ | 96 | - Mean age 48; - Turkey; - Metabolic syndrome | Poor | Ramipril vs. valsartan | 14.3 to 12.0 mmol/L^*^ vs. 14.9 to 12.6 mmol/L^*^ | 7.3 to 5.5 mmol/L^*^ vs. 7.7 to 6.1 mmol/L^*^ | 2.0 to 2.4 mmol/L^*^ vs. 1.9 to 2.3 mmol/L^*^ | 8.8 to 7.6 mmol/L^*^ vs. 11.0 to 8.9 mmol/L^*^
Xu et al., 2007^101^ | 96 | - Mean age 51; - China; - Abnormal serum lipids | Poor | Telmisartan vs. enalapril | 6.1 to 5.8 mmol/L vs. 6.1 to 5.9 mmol/L | 3.1 to 2.3 mmol/L vs. 3.1 to 3.0 mmol/L | 1.5 to 1.7 mmol/L^†^ vs. 1.4 to 1.4 mmol/L | 2.8 to 2.0 mmol/L^†^ vs. 2.8 to 2.6 mmol/L

* Statistically significant within-treatment change (baseline to followup)

† Statistically significant comparison between treatments

HDL = low-density lipoprotein; LDL = low-density lipoprotein; N = number of subjects; NR=not reported; TC = total cholesterol; TG = triglyceride

Twelve studies directly compared outcomes between ACEI and ARB groups.23,25,44,46,62,70,73,75,96,98,99,101 Of these 12, only two found different effects between the medications compared (Table 8). One study reported a decrease in LDL that was statistically greater in the ACEI group (perindopril -14 percent vs. candesartan -4 percent).23 Another study found a statistically greater decrease in triglyceride (telmisartan -28 percent vs. enalapril -6 percent, p < 0.01) and greater increase in HDL (telmisartan +18 percent vs. enalapril -3 percent, p < 0.05) for telmisartan compared with enalapril.101 Thus, for the two studies in which a difference between groups was found, the difference was discrepant (i.e., results favored ACEI in one study and favored ARB in the other). Of these two studies, only one was rated as good in quality.23

#### Effect on Markers of Carbohydrate Metabolism/Diabetes Control

Twenty-three studies described in 28 papers met our inclusion criteria and measured glucose or HbA1c. All but four80,96,99,110 were RCTs. Overall, only 3 studies were rated as good in quality;23,25,32 the remainder were rated as either fair (11 studies43,44,46,53,60,62,72,73,75,77,110) or poor (9 studies80,86,88,96,98,99,101,102,113). The ACEI-versus-ARB comparisons tested were unique in 14 studies; of the remaining 9 studies, enalapril and losartan were compared in 5,^53,75,80,96,99^ candesartan and lisinopril in 2,^32,60^ and perindopril and telmisartan in 2.^62,86^

It is relevant that none of the 23 studies measuring glucose or HbA1c changes addressed hypoglycemic therapy during the study period, and only 8 were specifically performed in diabetic populations.23,32,44,53,60,73,88,113 Of the other 15 studies, 4 permitted controlled diabetic patients but did not describe their proportion in the cohort;43,72,75,99 5 permitted diabetic subjects;62,77,96,98,110 and 6 specifically excluded individuals with diabetes.25,46,80,86,101,102

The majority of the available head-to-head evidence suggests that ACEIs and ARBs have a similar lack of impact on glucose levels or HbA1c. Twelve studies directly compared outcomes between the ACEI and ARB groups.23,25,44,46,62,72,75,80,99,101,110,113 One study reported a small decrease in glucose after 12 months that was statistically greater in the ACEI group (perindopril -15 ± 4 mg/dL, candesartan -8 ± 2 mg/dL),23 and one reported a significant increase in HbA1c (+ 0.25 percent enalapril vs. + 0.6 percent losartan) but did not directly compare the two groups.53 One study reported significantly lower 2-hour blood glucose levels at 6 months in the telmisartan group (5.48 mmol/L ± 1.46) compared with the enalapril group (6.70 mmol/L ± 1.41, p < 0.05).101 Of these three studies, only one23 was rated as good in quality. The other nine studies that analyzed differences in outcomes between the two groups did not find a difference. Sixteen studies compared baseline to followup glucose levels or HbA1c and found no change for either the ACEI or ARB groups.

#### Effect on Measures of LV Mass or Function

Thirteen studies presented results on LV mass or function assessed either by LV mass index (LVMI; 7 studies),31,33,34,41,80,99,107 LV ejection fraction (LVEF; 2 studies),81,93 both (3 studies),74,92,109 or LV posterior wall thickness.87 Table 9 summarizes relevant characteristics of all 13 studies. Six of these studies had fewer than 50 patients,33,41,74,80,87,93 2 had between 50 and 100 patients,31,99 and 5 had 100 or more patients.34,81,92,107,109 All but two studies80,99 were RCTs. Only two studies had relatively long-term followup (≥ 3 years);41,99 however, the majority of studies had between 6 and 12 months of followup,31,33,74,80,81,87,92,107,109 while one study had only 3 months of followup.93 Because duration of therapy may significantly impact the ability to observe changes in LV mass or function, negative results must be interpreted with caution in studies with short-term followup.

Table 9 Characteristics of studies reporting LV mass/function outcomes

Study | Agents studied | Population | Design and size^*^ | Duration | Quality | Outcome | Result
Cuspidi et al., 2002^109^ | Candesartan vs. enalapril | LVH (29–32%) | RCT N = 196 (145) | 48 wk | Fair | LVMI & LVEF | ↓LVMI both, no difference between agents, no change in LVEF
Spoelstra-de Man et al., 2006^33^ | Candesartan vs. lisinopril | DM and HTN (? %LVH) | RCT N = 46 | 12 mo | Good | LVMI | ↓LVMI both, but ARB not compared to ACEI
Schieffer et al., 2004^93^ | Irbesartan vs. enalapril | CAD (? %LVH) | RCT N = 60 (48) | 3 mo | Poor | LVEF | No difference No detailed data by treatment group
Guntekin et al., 2008^87^ | Irbesartan vs. quinapril | New HTN (? %LVH) | RCT N = 65 (38) | 12 mo | Poor | LV posterior wall thickness | ↓LV posterior wall thickness both, no difference reported between agents
Avanza et al., 2000^80^ | Losartan vs. enalapril | LVH (100%) | Non-rand controlled clinical trial N = 30 | 10 mo | Poor | LVMI | ↓LVMI both, no difference between agents, combo ACEI/ARB best
De Rosa et al., 2002^41^ | Losartan vs. enalapril | LVH (44–53%) | RCT N = 50 (42) | 3 yr | Fair | LVMI | Non-statistical ↓LVMI both, no difference between agents
Shibasaki et al., 2002^74^ | Losartan vs. enalapril | ESRD with LVH (100%) | RCT N = 20 | 6 mo | Fair | LVMI & LVEF | ↓LVMI both, ARB better than ACEI, no change in LVEF
Tedesco et al., 2006^34^ | Losartan vs. enalapril | HTN (30–33% LVH) | RCT N = 259 (185) | 2 yr | Good | LVMI | ↓LVMI both, ARB more than ACEI, but ARB higher baseline
Verdecchia et al., 2000^99^ | Losartan vs. enalapril | LVH (23–24%) | Case-control N = 88 | 3.3 yr | Poor | LVMI | ↓LVMI both, no difference between agents
Rajzer et al., 2003^92^ | Losartan vs. quinapril | HTN (? %LVH) | RCT N = 118 | 6 mo | Poor | LVMI & LVEF | No change in LVMI or LVEF in either group No detailed data by treatment group
Scaglione et al., 2007^31^ | Losartan vs. ramipril | HTN (53% LVH) | RCT N = 57 | 24 wks | Good | LVMI | ↓LVMI both, no difference between agents
Celik et al., 2005^81^ | Telmisartan vs. ramipril | HTN (? %LVH) | RCT N = 100 | 6 mo | Poor | LVEF | No change in LVEF in either group
Solomon et al., 2009^107^ | Aliskiren vs. losartan | HTN (100% LVH) | RCT N = 465 (400) | 34 wks | Good | LVMI | ↓LVMI both, no difference between groups (aliskiren, ARB, combination)

* Size of study includes total enrolled in ACEI, ARB, direct renin inhibitor, or combination arms, with relevant followup population (if different) in parentheses.

CAD = coronary artery disease; ESRD = end-stage renal disease; HTN = hypertension; LVEF = left ventricular ejection fraction; LVH = left ventricular hypertrophy; LVMI = left ventricular mass index; mo = months; RCT = randomized controlled trial; wk = weeks; yr = years

Evidence provided by the 13 studies identified did not demonstrate a difference between ACEIs and ARBs with regard to LV mass or function for individuals with essential hypertension. Ten studies reported detailed data by treatment groups,31,33,34,41,74,80,81,99,107,109 while one reported summary data,92 and two described changes without presenting any data.87,93 In general, the quality ratings of these studies describing changes in LV mass or function was poor,80,81,87,92,93,99 although some of the more recent ones were rated as being good-quality studies.31,33,34,107 Various ARBs and ACEIs were studied, including seven studies with losartan31,34,41,74,80,92,99 and seven studies with enalapril.34,41,74,80,93,99,109 Only one study evaluated the newer direct renin inhibitor, aliskiren.107 Among the nine studies that presented detailed data on outcomes, six assessed LVMI,31,34,41,80,99,107 one assessed LVEF,81 and two assessed both LVMI and LVEF.74,109

The best and largest (n = 259) comparative study (an RCT) assessed LVMI at baseline and after 24 months of followup.34 The authors reported similar decreases in mean LVMI in both groups in per-protocol analyses (12.3 percent on losartan versus 7.5 percent on enalapril). The trial with the longest followup (3 years; RCT) also reported similar reductions in mean LVMI in both groups; however, these changes did not reach statistical significance.41 Two nonrandomized studies reported similar decreases in LVMI,80,99 with one80 demonstrating additional benefit in LVMI reduction with combination ACEI and ARB therapy. Only one study demonstrated a difference between groups for reduction in LVMI,74 with lower reduction among those treated with losartan versus enalapril (24.7 ± 3.2 percent vs. 11.2 ± 4.1 percent; p = 0.026). However, definitive conclusions from this study are limited because it was conducted in patients with end-stage renal disease, included only 10 patients per treatment group, and had only moderate duration of followup (6 months). Finally, among the studies that reported results for LVEF, none demonstrated any differential effects between the ACEI and ARB groups.

Despite differences in sample size, study design, length of followup, study quality, therapeutic agents, and outcome measure, most of the studies demonstrated either similar improvements in LV mass or function between the ACEI and ARB groups31,33,34,74,80,87,99,109 or no change.41,92 Similar improvements in LV mass were also observed in the direct renin inhibitor study.107 Reductions in LVMI appear to have occurred particularly among patients with established LV hypertrophy.41,74,80,109 No changes in LVEF were observed in any of the studies. In sum, this body of poor- to fair-quality evidence does not demonstrate any differential effects in the ability of ACEIs, ARBs, and direct renin inhibitors to improve or stabilize LVMI in patients with essential hypertension.

#### Effect on Serum Creatinine/GFR and Proteinuria

##### Overview

Review of the literature on the relative effects of ACEIs, ARBs, and direct renin inhibitors on changes in intermediate renal outcomes identified 31 studies described in 38 publications. One of these studies was conducted in patients with end-stage renal disease who had been on maintenance hemodialysis for at least 1 month.74 This study is not considered further here, as no changes would be expected in the outcome assessed (serum creatinine) in the population studied. Of the remaining 30 studies, 12 assessed either serum creatinine or GFR;25,41,43,44,59,69,77,80,94,98,99,105 6 assessed proteinuria;23,28,32,60,103,115 and 12 assessed both.37,42,53,62,70,73,75,78,88,90,110,113 Most studies included fewer than 100 patients; however, 10 had approximately 200 patients or more.37,43,59,60,69,73,75,98,104,105 All but five80,99,110,113,115 were RCTs. One study37 followed patients for 5 years, and approximately half of the studies had at least 1 year of followup; however, four studies followed patients for less than 4 months.44,59,75,94

##### Results for Creatinine-Related Outcomes

The 24 studies that described changes in creatinine or GFR did not consistently demonstrate differential effects related to renal function with use of ACEIs versus ARBs. Seventeen of these studies reported detailed data by treatment groups,25,37,41,42,44,59,62,73,77,78,80,88,94,99,105,110,113 while three reported summary data,53,75,98 and five described the changes without presenting any quantitative data.43,69,70,90,104 Among the 17 studies that reported data on renal function, 2 were rated as being good-quality studies;25,105 5 were of poor quality;80,88,94,99,113 4 were nonrandomized studies;80,99,110,113 and 5 had more than 100 patients.25,37,59,73,105 All but seven37,59,62,73,78,110,113 compared losartan with a specific ACEI; the ACEI most frequently studied was enalapril.25,37,41,80,94,99 Studies comparing direct renin inhibitors with either ACEIs or ARBs also did not demonstrate differential effects related to renal function, but they were generally larger and of higher quality.104,105

The best comparative study assessed GFR by renal scintigraphy at baseline and after 3 years of followup.41 The authors reported increases in mean GFR in both groups, but there was no statistically significant difference between groups. One of the larger studies in this group (n = 190) reported a greater short-term increase (12-week study) in mean serum creatinine in the enalapril group (change 0.03 mg/dL [95% CI 0 to 0.06]) compared with the irbesartan group (change 0.01 mg/dL [95% CI -0.02 to 0.04]).59

Among seven fair- to good-quality studies that reported on changes in renal function, all reported small differences during treatment without differences by class of angiotensin antagonist.25,42,62,73,78,105,110 Of two poor-quality studies that reported on changes in creatinine clearance, one reported no change.94 Although the other study reported significant and similar decreases in creatinine clearance in both groups,88 these changes did not correspond to the changes in serum creatinine reported, which calls into question the reliability of the data. Of the two studies that reported summary data, one found a 9 percent mean decline in GFR assessed by radio-labeled excretion in each group (p < 0.001 at 52 weeks),53 while the other found no change in mean percent change in serum creatinine.75 Of the five studies that did not present detailed data, two reported that there were no overall differences between groups;70,90 another reported that the degree and direction of insignificant change in renal function were comparable in both treatment groups;43 and the last two described that a few patients developed an increase in serum creatinine: 2 out of 192 patients treated with losartan developed an increase in serum creatinine during the 12-week study,69 while 3 out of 422 patients treated with ramipril developed an increase in serum creatinine during the 26-week study.103

##### Meta-Analyses of Studies Reporting Creatinine-Related Outcomes

Several studies reported pre- and post-treatment creatinine-related values. These included serum creatinine, creatinine clearance, and GFR. Using the pre- to post-treatment difference as an endpoint requires the standard deviation of the difference or the intra-class correlation. In most cases, neither was available. For this reason we chose to look at the posttreatment values without reference to the pretreatment values. We used the standardized difference in means (ARB mean minus ACEI mean) as our effect measure.

Table 10 gives a summary of the studies reporting serum creatinine and their estimated standardized mean differences. Note that when several trials assessed the same outcome using different scales, we used a standardized mean difference to convert all outcomes to a common scale, measured in units of standard deviations.

Table 10 Estimated standardized mean differences for studies reporting serum creatinine (ARB minus ACEI)

Study | Mean difference | Standard error | Variance | Study type
Avanza et al., 2000^80^ | 0.000 | 0.365 | 0.133 | OBS
Verdecchia et al., 2000^99^ | 0.133 | 0.246 | 0.061 | OBS
Ozturk et al, 2009^113^ | 0.156 | 0.204 | .041 | OBS
Fogari et al., 2002^44^ | 0.000 | 0.217 | 0.047 | RCT
Uchiyama-Tanaka et al., 2005^77^ | 0.000 | 0.309 | 0.096 | RCT
Hermida et al., 2008^25^ | 0.143 | 0.165 | 0.027 | RCT
Zhu et al., 2008^78^ | 0.138 | 0.259 | 0.067 | RCT
Nakamura et al., 2009^62^ | 0.190 | 0.275 | 0.076 | RCT

OBS = observational study; RCT = randomized controlled trial

We summarized all studies together, as well as analyzing certain subgroups. We compared RCTs to observational studies. The results are summarized in Table 11. The analyses include measures of homogeneity (Q-statistic).

Table 11 Meta-analyses of serum creatinine by subgroup for ARB minus ACEI

Model | Analysis subgroup | No. of studies | Mean difference | 95% CI lower limit | 95% CI upper limit | Z value | P value | Q value | df (Q) | P value
Fixed | All | 8 | 0.109 | -0.054 | 0.272 | 1.311 | 0.190 | 0.668 | 7 | 0.999
Random | All | 8 | 0.109 | -0.054 | 0.272 | 1.311 | 0.190
Fixed | Observ | 3 | 0.124 | -0.159 | 0.406 | 0.857 | 0.391 | 0.141 | 2 | 0.763
Random | Observ | 3 | 0.124 | -0.159 | 0.406 | 0.857 | 0.391
Fixed | RCT | 5 | 0.102 | -0.098 | 0.301 | 1.000 | 0.317 | 0.512 | 4 | 0.989
Random | RCT | 5 | 0.102 | -0.098 | 0.301 | 1.000 | 0.317

CI = confidence interval; df = degrees of freedom; Observ = observational study; RCT = randomized controlled trial

The results for the random-effects analysis of all studies are shown in Figure 5.

Figure 5 Random-effects analysis of all studies reporting serum creatinine (ARB mean minus ACEI mean)

Figure 5 displays a forest plot of studies reporting the standard difference of means for serum creatinine, ARBs versus ACEIs. In the 8 studies the combined estimated standardized mean difference was 0.109 (95% CI -0.054 to 0.272), suggesting that mean posttreatment creatinine levels are slightly higher for the ARB studies, but the difference is clearly not statistically significant.

The analysis of all studies gave an estimated standardized mean difference of 0.109 (95 percent CI -0.054 to 0.272), suggesting that mean post-treatment creatinine levels are slightly higher for the ARB studies, but the difference is clearly not statistically significant.

Table 12 gives a summary of the studies reporting creatinine clearance and their estimated standardized mean differences.

Table 12 Estimated standardized mean differences for studies reporting creatinine clearance (ARB minus ACEI)

Study | Mean difference | Standard error | Variance | Study type
Shand et al., 2000^94^ | -0.770 | 0.385 | 0.148 | RCT
Kavgaci et al., 2002^88^ | -0.241 | 0.389 | 0.151 | RCT
Deyneli et al., 2006^42^ | -0.100 | 0.409 | 0.167 | RCT
Sengul et al., 2006^73^ | -0.085 | 0.204 | 0.042 | RCT

We summarized all studies. The results are summarized in Table 13. The analyses include measures of homogeneity (Q-statistic)

Table 13 Meta-analyses of creatinine clearance for ARB minus ACEI

Model | Analysis subgroup | No. of studies | Mean difference | 95% CI lower limit | 95% CI upper limit | Z value | P value | Q value | df (Q) | P value
Fixed | All | 4 | -0.217 | -0.515 | 0.080 | -1.4315 | 0.1523 | 2.567 | 3 | 0.4633
Random | All | 4 | -0.217 | -0.515 | 0.080 | -1.4315 | 0.1523

CI = confidence interval; df = degrees of freedom

The results for the random-effects analysis of all studies are shown in Figure 6.

Figure 6 Random-effects analysis of all studies reporting creatinine clearance (ARB mean minus ACEI mean)

Figure 6 displays a forest plot of studies reporting the standard difference of means for creatinine clearance, ARBs versus ACE inhibitors. In the four studies the combined estimated standardized mean difference was 0.217 (95% CI -0.080 to 0.515), suggesting that mean posttreatment creatinine clearance levels are slightly lower for the ARB studies, but the difference is not statistically significant (p = 0.1523).

The analysis of all studies gave an estimated standardized mean difference of 0.217 (95% CI -0.080 to 0.515), suggesting that mean post creatinine clearance levels are slightly lower for the ARB studies, but the difference is not statistically significant (p = 0.1523).

Table 14 gives a summary of the studies reporting GFR and their estimated standardized mean differences.

Table 14 Estimated standardized mean differences for studies reporting GFR (ARB minus ACEI)

Study | Mean difference | Standard error | Variance | Study type
Cotter, et al., 2008^110^ | -0.608 | 0.245 | 0.060 | OBS
Derosa et al., 2003^23^ | -0.336 | 0.285 | 0.081 | RCT
Barnett et al., 2004^37^ | -0.248 | 0.137 | 0.019 | RCT
Duprez, et al., 2010^105^ | 0.000 | 0.067 | 0.004 | RCT

OBS = observational study; RCT = randomized controlled trial

We summarized all studies. The results are summarized in Table 15. The analyses include measures of homogeneity (Q-statistic).

Table 15 Meta-analyses of GFR for ARB minus ACEI

Model | Analysis subgroup | No. of studies | Mean difference | 95% CI lower limit | 95% CI upper limit | Z value | P value | Q value | df (Q) | P value
Fixed | All | 4 | -0.089 | -0.201 | 0.022 | -1.5691 | 0.1166 | 8.377 | 3 | 0.0388
Random | All | 4 | -0.227 | -0.486 | 0.032 | -1.7154 | 0.0863

CI = confidence interval; df = degrees of freedom

The results for the random-effects analysis of all studies are shown in Figure 7.

Figure 7 Random-effects analysis of all studies reporting GFR (ARB mean minus ACEI mean)

Figure 7 displays a forest plot of studies reporting the standard difference of means for GFR, ARBs versus ACEIs. In the 4 studies the combined estimated standardized mean difference was 0.227 (95% CI -0.032 to 0.486), suggesting that mean post-treatment GFRs are slightly lower for the ARB studies, and the difference is marginally statistically significant (p = 0.0863).

The analysis of all studies gave an estimated standardized mean difference of 0.227 (95% CI -0.032 to 0.486), suggesting that mean post-treatment GFRs are slightly lower for the ARB studies, and the difference is marginally statistically significant (p = 0.0863).

Table 16 summarizes results for both flow rates from all studies. The analyses include measures of homogeneity (Q-statistic).

Table 16 Meta-analyses of all flow rate studies for ARB minus ACEI

Model | Analysis subgroup | No. of studies | Mean difference | 95% CI lower limit | 95% CI upper limit | Z value | P value | Q value | df (Q) | P value
Fixed | All | 8 | -0.105 | -0.210 | -0.001 | -1.9720 | 0.0486 | 11.566 | 7 | 0.1158
Random | All | 8 | -0.212 | -0.396 | -0.028 | -2.2617 | 0.0237

CI = confidence interval; df = degrees of freedom; GFR = glomerular filtration rate

The analysis of all flow studies gave an estimated standardized mean difference of -0.227 (95% CI -0.396 to -0.028), suggesting that mean flow rates are slightly lower for the ARB studies, and the difference is statistically significant (p = 0.0237).

##### Results for Proteinuria

The 18 studies that described changes in urine albumin or protein excretion consistently demonstrated no differential effects related to reduction of urinary protein or albumin excretion among patients with essential hypertension with use of ACEIs versus ARBs. Overall fair in quality, 16 of 18 studies reported detailed data by treatment groups, while two reported summary data in graphical format.32,110 Among the 16 studies that reported data, 2 were rated as being good-quality studies,23,28 4 were of poor quality;88,90,113,115 2 were nonrandomized cohort studies;113,115 and only 4 had more than 100 patients.28,37,60,75 Various ARBs were used, including two studies with telmisartan,37,73 four studies with candesartan,23,60,70,115 four with losartan,42,53,75,88 one with both candesartan and losartan,90 and two with valsartan.28,78 All studies assessed urinary albumin excretion except for two studies that assessed urinary protein excretion.90,113 Studies also varied in length of followup, with only one long-term study (5 years);37 the remainder ranged from 12 weeks to 2 years. However, despite these differences in study quality, sample size, therapeutic agents, outcome measure and length of followup, all of the studies demonstrated declines in urinary protein/albumin excretion that were similar between the ACEI and ARB groups. In the only study that described changes among patients with essential hypertension treated with aliskiren, a greater reduction in urinary albumin to creatinine ratio was observed overall, but there were no differences among those with baseline microalbuminuria or proteinuria.104

#### Discussion

The lack of an apparent differential impact of ACEIs versus ARBs on intermediate renal parameters must be considered in light of concerns about the available literature. Some concerns may reinforce the conclusion. For example, the study by Matsuda et al.90 provided sufficient data only on the subgroup of patients with moderate proteinuria and thus would likely favor ACEIs, yet there were no significant differential effects between the ACEI and ARB groups within the entire study sample after 48 weeks (p > 0.5). Numerous other studies also failed to demonstrate a differential effect. On the other hand, because duration of therapy may significantly impact the ability to observe meaningful changes in renal function or proteinuria, negative results must be interpreted with caution in studies with short-term followup.

## Key Question 2 For adult patients with essential hypertension, how do ACEIs, ARBs, and direct renin inhibitors differ in safety, adverse events, tolerability, persistence with drug therapy, and treatment adherence?

### Key Points

- Cough was more frequently observed as an adverse event in groups treated with ACEIs than in groups treated with ARBs or direct renin inhibitors.
- Withdrawals due to adverse events were modestly more frequent for groups receiving an ACEI rather than an ARB or direct renin inhibitor; this is consistent with differential rates of cough.
- No significant between-class differences were observed in the rates of any other commonly reported adverse events.
- Angioedema was not reported in the majority of studies, making it impossible to accurately characterize its frequency and timing in this population. In the studies that did report episodes of angioedema, this adverse event was observed only in patients treated with an ACEI or a direct renin inhibitor.
- Treatment adherence—in terms of pill counts in RCTs—is similarly high with both ACEIs and ARBs. However, persistence with drug therapy is generally lower with ACEIs, which may be explained largely by withdrawals due to cough (as above). None of the included direct renin inhibitor studies reported adherence or persistence.
- New cancer diagnoses were not reported in any of our included studies, and we were not able to provide further evidence on an association with ARBs, ACEIs or direct rennin inhibitors.

### Safety and Adverse Events

#### Rates of Serious and Overall Adverse Events

Fourteen studies met our inclusion criteria and reported overall rates of serious adverse events.25-28,51,59,69,70,79,98,103,106-108 Six of these studies were rated as good in methodological quality, seven were rated as fair, and one was poor. However, the nature of serious adverse event reporting was inconsistent, and rates of serious adverse events were low (on the order of 0 to 6 percent, depending on definition); thus, data on these events were not deemed useful for assessing a differential effect of ACEIs versus ARBs.

A potentially salient and serious adverse event, angioedema, has been reported to occur in ACEI-treated patients with much greater frequently than in ARB-treated patients.112 However, this outcome was reported in only four studies (Table 17).51,58,63,103 One of the reported cases occurred in a patient treated with a direct renin inhibitor; the other cases were in patients treated with an ACEI. We did not pool these studies because in studies that did not report angioedema, it was not clearly valid to infer that there were no events simply because the studies did not report explicitly that an episode of angioedema did not occur. Thus, we are unable to estimate the frequency of angioedema in this population.

Table 17 Studies reporting angioedema

Study | Study design (blinding) | Interventions (numbers of patients) | Duration | Quality | Results
Andersen et al., 2008^103^ | RCT (double-blinded) | Ramipril (n = 422) Aliskiren (n = 420) | 26 weeks | Good | No cases of angioneurotic edema with ramipril 1 case angioneurotic edema in one patient receiving aliskiren
Karlberg et al., 1999^51^ | RCT (double-blinded) | Telmisartan (n = 139) Enalapril (n = 139) | 26 weeks | Fair | No cases of angioedema with telmisartan 1 case (“severe disabling Quincke's angioneurotic edema”) with enalapril
McInnes et al., 2000^58^ | RCT (double-blinded) | Candesartan (n = 237) Lisinopril (n = 116) | 26 weeks | Fair | No cases of angioedema with candesartan 2 cases with lisinopril
Neutel et al., 1999^63^ | RCT (double-blinded) | Telmisartan (n = 385) Lisinopril (n = 193) | 48 weeks | Fair | No cases of angioedema with telmisartan 2 cases with lisinopril

Of the 47 studies that met inclusion criteria and reported overall adverse event rates,23-31,34,35,37,38,40,42,43,45,47,51,52,54,56-59,62,63,69,70,73,75,76,78,79,82,85,89,91,94,98,101,103,105-109 only 15 were assessed as being good in quality. There was significant variation across studies in the manner in which adverse events data were collected and reported. Several studies reported only “severe” or “major” adverse events, and no consistent method was used across studies to classify the severity of events. For these reasons, data on overall rates of adverse events were not considered further.

#### Specific Adverse Events

Forty-eight studies reported rates of one or more specific adverse events,23-31,34,35,38,40-43,45,47,51-54,56-59,61-63,69,73,75,76,78,79,89,91,98,101,103,105-109,115-117 including cough (42 studies), dizziness (31 studies), headache (30 studies), fatigue or asthenia (17 studies), upper respiratory infection (11 studies), nausea (12 studies), diarrhea (5 studies), and dyspepsia (5 studies). Back pain and hypotension were each reported as an adverse event in four studies. Viral infection, sinusitis, peripheral edema, and nasophyrangitis were reported as adverse events by three studies each. Palpitations, myalgia, malaise, urinary tract infection, vertigo, hypertensive crisis, abnormal taste, and musculoskeletal pain were reported by two studies each. Accident/injury, pharyngitis, rhinitis, dyspnea, abdominal pain, constipation, dry mouth, feeling sick, pyrosis, insomnia, fever, impotence, flatulence, epigastric discomfort, increased sweating, erythematous rash, flushing, cold hands/feet, atrial flutter, death, cor pulmonale, heartburn, oral erythema, instable deambulance, adverse events related to the nervous system, adverse events related to the cardiovascular system, and adverse events related to the gastrointestinal system were reported as a specific adverse events by one study each.

Given the large number of commonly reported specific adverse events, we focused on three specific events with the largest difference in absolute rates across studies: dizziness, headache, and cough. Rates of dizziness in studies reporting this event (n = 31) ranged from 1 to 20 percent in ARB-treated groups (mean 3.7 percent), from 0 to 18 percent in ACEI-treated groups (mean 4.4 percent), and from 3 to 8 percent in the three studies involving direct renin inhibitors (mean 6.0 percent). For headache (n = 30 studies), rates ranged from 1 to 22 percent in ARB-treated groups (mean 5.8 percent), from 0 to 34 percent in ACEI-treated groups (mean 7.0 percent) and 9 to 11 percent in direct renin inhibitor-treated groups (mean 10.0 percent). These results suggest that there is no differential impact of ACEIs and ARBs or direct renin inhibitors with regard to dizziness or headache.

The one adverse event for which significant differential effects were apparent is cough. Forty-two studies reported cough as an adverse event; of these, 40 studies compared cough in subjects treated with ACEIs or ARBs, and two compared cough rates in subjects treated with an ACEI or a direct renin inhibitor.103,105 The single eligible study that compared adverse events between an ARB and a renin inhibitor107 did not report cough as an adverse event in either treatment arm. In terms of quality, 9 of the 42 studies were rated as good, 26 as fair, and 7 as poor. Thirty-nine of the studies were RCTs, two were prospective cohort studies, and one was a cross-sectional cohort study. Sample sizes for the studies ranged from 24 to 51,410 patients, with a total of 68,875 patients. Study durations ranged from 12 weeks to 3 years. The mean patient age of study participants was 58 years. The proportion of female patients included ranged from 24 to 100 percent (mean 48 percent). Twenty-four studies (57 percent) reported the racial demographics of the study participants. Of these 24 studies, 11 (46 percent) enrolled a minimum of 10 percent of ethnic minority participants.

Rates of cough in these studies ranged from 0 to 13 percent for ARB-treated groups (mean 2.2 percent), and from 0 to 23 percent in ACEI-treated groups (mean 8.7 percent). Cough rates associated with direct renin inhibitors were 4.1 and 4.2 percent in the two studies that compared an ACEI with a direct renin inhibitor.103,105 All 40 studies that compared cough rates between ACEI and ARB treatments demonstrated higher rates of cough in ACEI-treated participants, but statistical significance was not always reported, and the magnitude of the differences in rates were sometimes small.

For the meta-analysis of studies reporting cough as an adverse event, we included all 40 studies that reported on cough rates. Table 18 gives a summary of the studies and their estimated odds ratios. The odds ratio represents the odds of having a cough for the ARB patients divided by the odds of having a cough for the ACEI patients.

Table 18 Estimated odds ratios for cough (ARBs vs. ACEIs)

Study | Odds ratio | Ln(OR) | Standard error | Study type
Mackay et al., 1999^117^ | 0.284 | -1.259 | 0.132 | OBS
Gregoire et al., 2001^116^ | 0.300 | -1.202 | 0.533 | OBS
Sato et al., 2003^115^ | 0.162 | -1.819 | 1.576 | OBS
Tikkanen et al., 1995^75^ | 0.072 | -2.631 | 0.742 | RCT
Townsend et al., 1995^76^ | 0.246 | -1.402 | 0.800 | RCT
Ruff et al., 1996^29^ | 0.638 | -0.450 | 0.807 | RCT
Black et al., 1997^38^ | 0.127 | -2.060 | 0.570 | RCT
Larochelle et al., 1997^54^ | 0.168 | -1.781 | 0.697 | RCT
Roca-Cusachs et al., 1997^69^ | 0.905 | -0.100 | 0.407 | RCT
Mimran et al., 1998^59^ | 0.446 | -0.807 | 0.482 | RCT
Elliott, 1999^43^ | 0.514 | -0.666 | 0.236 | RCT
Karlberg et al., 1999^51^ | 0.368 | -0.999 | 0.416 | RCT
Naidoo et al., 1999^61^ | 0.363 | -1.012 | 0.362 | RCT
Neutel et al., 1999^63^ | 0.411 | -0.888 | 0.404 | RCT
Lacourciere et al., 2000^53^ | 0.057 | -2.873 | 1.475 | RCT
Malmqvist et al., 2000^57^ | 0.023 | -3.761 | 1.437 | RCT
McInnes et al., 2000^58^ | 0.160 | -1.830 | 0.379 | RCT
Ruilope et al., 2001^30^ | 0.092 | -2.390 | 1.055 | RCT
Amerena et al., 2002^35^ | 0.078 | -2.551 | 0.743 | RCT
Coca et al., 2002^40^ | 0.095 | -2.349 | 1.058 | RCT
Cuspidi et al., 2002^109^ | 0.275 | -1.290 | 0.665 | RCT
De Rosa et al., 2002^41^ | 0.280 | -1.273 | 1.192 | RCT
Ragot et al., 2002^91^ | 0.160 | -1.834 | 0.770 | RCT
Derosa et al., 2003^23^ | 0.200 | -1.609 | 1.563 | RCT
Fogari et al., 2004^45^ | 0.240 | -1.428 | 1.130 | RCT
Malacco et al., 2004^26^ | 0.129 | -2.049 | 0.439 | RCT
Koylan et al., 2005^89^ | 0.087 | -2.446 | 0.613 | RCT
Deyneli et al., 2006^42^ | 0.307 | -1.182 | 1.683 | RCT
Fogari, et al., 2006^47^ | 0.195 | -1.635 | 1.557 | RCT
Lacourciere et al., 2006^106^ | 0.028 | -3.574 | 1.018 | RCT
Tedesco et al., 2006^34^ | 0.108 | -2.226 | 1.496 | RCT
Williams et al., 2006^108^ | 0.084 | -2.478 | 0.741 | RCT
Xu et al., 2007^101^ | 0.209 | -1.567 | 1.563 | RCT
Fogari et al., 2008^24^ | 0.109 | -2.214 | 1.496 | RCT
Kloner et al., 2008^52^ | 0.150 | -1.898 | 1.518 | RCT
Zhu et al., 2008^78^ | 0.187 | -1.677 | 1.571 | RCT
Nakamura et al., 2009^62^ | 0.192 | -1.648 | 1.574 | RCT
Spinar et al., 2009^98^ | 0.122 | -2.105 | 0.530 | RCT
Akat et al., 2010^79^ | .099 | -2.317 | 1.511 | RCT
Malacco et al., 2010^27^ | 0.152 | -1.884 | 0.762 | RCT

Ln(OR) = natural log of odds ratio; OBS = observational study; RCT = randomized controlled trial

We summarized all studies, as well as comparing RCTs to observational studies. The results are summarized in Table 19. The analyses include measures of homogeneity (Q-statistic).

Table 19 Meta-analyses of cough by subgroup for ARBs versus ACEIs

Model | Analysis subgroup | No. of studies | OR estimate | 95% CI lower limit | 95% CI upper limit | Z value | P value | Q value | df (Q) | P value
Fixed | All | 40 | 0.268 | 0.229 | 0.313 | -16.473 | 0.0000 | 55.770 | 39 | 0.040
Random | All | 40 | 0.228 | 0.180 | 0.290 | -12.115 | 0.0000 | - | - | -
Fixed | Observ | 3 | 0.284 | 0.221 | 0.365 | -9.841 | 0.0000 | 0.137 | 2 | 0.934
Random | Observ | 3 | 0.284 | 0.221 | 0.365 | -9.841 | 0.0000 | - | - | -
Fixed | RCTs | 37 | 0.257 | 0.211 | 0.315 | -13.224 | 0.0000 | 55.276 | 36 | 0.021
Random | RCTs | 37 | 0.210 | 0.158 | 0.279 | -10.713 | 0.0000 | - | - | -

CI = confidence interval; df = degrees of freedom; Observ = observational studies; OR = odds ratio; RCTs = randomized controlled trials

The results for the random-effects analysis of RCTs are in Figure 8. Analysis of the potential for publication bias is provided in Appendix H.

Figure 8 Random-effects analysis of RCTs for cough (ARBs vs. ACEIs)

Figure 8 displays a forest plot of RCT studies reporting the odds ratio for cough, ARBs versus ACEIs. In the 37 studies, the combined estimated odds ratio was 0.211 (95% CI 0.159 to 0.281) suggesting that the odds of having a cough is only one-fifth as large with an ARB as it is with an ACEI.

The results are best summarized by the random-effects analysis of the RCTs. This analysis gave an estimated odds ratio of 0.211 (95% CI 0.159 to 0.281) suggesting that the odds of having a cough is only one-fifth as large with an ARB as it is with an ACEI.

These odds ratios need to be compared against the overall cough rate for ACEIs. The Mackay et al. observational study117 (which is by far the largest study) would suggest that this rate is about 1.5 percent. If we pool all of the RCTs, we get a rate of about 9.9 percent.

There were two studies (both RCTs) comparing a direct renin inhibitor with an ACEI. Their results are summarized in Table 20.

Table 20 Meta-analyses of cough for direct renin inhibitors vs. ACEIs

Model | Analysis subgroup | No. of studies | OR estimate | 95% CI lower limit | 95% CI upper limit | Z value | P value | Q value | df (Q) | P value
Fixed | RCTs | 2 | 0.3325 | 0.2241 | 0.4933 | -5.4704 | 0.0000 | 0.7622 | 1 | 0.3826
Random | RCTs | 2 | 0.3325 | 0.2241 | 0.4933 | -5.4704 | 0.0000 | - | - | -

CI = confidence interval; df = degrees of freedom; OR = odds ratio; RCTs = randomized controlled trials

This analysis gave an estimated odds ratio of 0.333 (95 percent CI 0.2241 to 0.4933), suggesting that the odds of having a cough is only one-third as large with a direct renin inhibitor as it is with an ACEI.

#### Withdrawals Due to Adverse Events

Forty-one studies met our inclusion criteria and reported withdrawals due to adverse events.24-28,31-35,37,38,40-43,47,51-53,56,58-63,69,75,76,78,80,89,94,99,101,103,105-107,109 Of these, 12 (29 percent) were of good methodological quality, 24 (59 percent) were fair in quality, and 5 (12 percent) were poor. Thirty-nine studies were RCTs, one was a nonrandomized controlled clinical trial, and one was a case-control study. Sample sizes for the individual studies ranged from 46 to 1,213 patients, with a total of 13,286 patients. Study durations ranged from 12 weeks to 5 years. The proportion of female patients included ranged from 24 to 100 percent (mean 48 percent). Twenty-one studies (51 percent) reported the racial demographics of the study participants. Ten of these (24 percent of the 41 total studies) enrolled a minimum of 10 percent of ethnic minority participants, while 6 enrolled only white patients.

Rates of withdrawals due to adverse events ranged from 1 to 20 percent, with a mean of 3 percent for patients on ARBs, and a mean of 5.5 percent for patients on ACEIs. Thirty-six trials reported withdrawals due to adverse events for both ACEIs and ARBs; in 28 of these trials (78 percent) there were more withdrawals in the ACEI-treated groups. However, there was significant variation in the study protocols and data reporting.

We conducted a meta-analysis of the 36 studies that reported withdrawals due to adverse events for both ACEIs and ARBs. Table 21 gives a summary of the studies and their estimated odds ratios. The odds ratio represents the odds of withdrawing for the ARB patients divided by the odds of withdrawing for the ACEI.

Table 21 Estimated odds ratios for withdrawals due to adverse events (ARBs vs. ACEIs)

Study | Odds ratio | Ln(OR) | Standard error | Study type
Avanza et al., 2000^80^ | 0.2635 | -1.3337 | 1.5177 | OBS
Verdecchia et al., 2000^99^ | 0.4500 | -0.7985 | 0.8074 | OBS
Mallion et al., 1995^56^ | 0.9899 | -0.0102 | 0.5749 | RCT
Tikkanen et al., 1995^75^ | 0.4176 | -0.8731 | 0.4984 | RCT
Townsend et al., 1995^76^ | 0.7561 | -0.2796 | 0.4590 | RCT
Black et al., 1997^38^ | 0.8950 | -0.1109 | 0.4526 | RCT
Roca-Cusachs et al., 1997^69^ | 0.4128 | -0.8849 | 0.6004 | RCT
Mimran et al., 1998^59^ | 3.1895 | 1.1599 | 1.1635 | RCT
Elliott, 1999^43^ | 1.0000 | 0.0000 | 1.4169 | RCT
Karlberg et al., 1999^51^ | 0.6606 | -0.4145 | 0.4115 | RCT
Naidoo et al., 1999^61^ | 0.9827 | -0.0175 | 0.8236 | RCT
Neutel et al., 1999^63^ | 0.0602 | -2.8097 | 1.0644 | RCT
Lacourciere et al., 2000^53^ | 2.0000 | 0.6931 | 1.2410 | RCT
McInnes et al., 2000^58^ | 0.4574 | -0.7822 | 0.3964 | RCT
Mogensen et al., 2000^60^ | 0.9688 | -0.0317 | 1.0158 | RCT
Shand et al., 2000^94^ | 0.2903 | -1.2368 | 1.6749 | RCT
Amerena et al., 2002^35^ | 0.4808 | -0.7324 | 0.6187 | RCT
Coca et al., 2002^40^ | 0.6850 | -0.3783 | 0.9227 | RCT
Cuspidi et al., 2002^109^ | 0.4700 | -0.7550 | 0.5116 | RCT
De Rosa et al., 2002^41^ | 0.1159 | -2.1550 | 1.5395 | RCT
Barnett et al., 2004^37^ | 0.6667 | -0.4055 | 0.3215 | RCT
Malacco et al., 2004^26^ | 0.3854 | -0.9535 | 0.3975 | RCT
Koylan et al., 2005^89^ | 0.0174 | -4.0531 | 1.4315 | RCT
Schram et al., 2005^32^ | 3.0000 | 1.0986 | 1.1952 | RCT
Deyneli et al., 2006^42^ | 0.3067 | -1.1820 | 1.6833 | RCT
Fogari, et al., 2006^47^ | 0.4872 | -0.7191 | 0.8809 | RCT
Lacourciere et al., 2006^106^ | 0.5098 | -0.6738 | 0.3633 | RCT
Spoelstra-de Man et al., 2006^33^ | 3.0000 | 1.0986 | 1.1952 | RCT
Tedesco et al., 2006^34^ | 0.3937 | -0.9322 | 0.8461 | RCT
Xu et al., 2007^101^ | 0.2086 | -1.5673 | 1.5627 | RCT
Fogari et al., 2008^24^ | 0.1967 | -1.6261 | 1.1030 | RCT
Hermida et al., 2008^25^ | 2.0000 | 0.6931 | 1.2353 | RCT
Kloner et al., 2008^52^ | 0.3561 | -1.0326 | 1.6388 | RCT
Menne et al., 2008^28^ | 0.8063 | -0.2154 | 0.7947 | RCT
Zhu et al., 2008^78^ | 0.1869 | -1.6773 | 1.5709 | RCT
Nakamura et al., 2009^62^ | 0.1925 | -1.6479 | 1.5738 | RCT

Ln(OR) = natural log of odds ratio; OBS = observational study; RCT = randomized controlled trial

We summarized all studies, as well as comparing RCTs to observational studies. The results are summarized in Table 22. The analyses include measures of homogeneity (Q-statistic). Analysis of the potential for publication bias is provided in Appendix H.

Table 22 Meta-analyses of withdrawals due to adverse events by subgroup for ARBs vs. ACEIs

Model | Analysis subgroup | No. of studies | OR estimate | 95% CI lower limit | 95% CI upper limit | Z value | P value | Q value | df (Q) | P value
Fixed | All | 36 | 0.5599 | 0.4500 | 0.6966 | -5.2027 | 0.0000 | 28.8562 | 35 | 0.7584
Random | All | 36 | 0.5599 | 0.4500 | 0.6966 | -5.2027 | 0.0000 | - | - | -
Fixed | Obs | 2 | 0.3999 | 0.0989 | 1.6169 | -1.2859 | 0.1985 | 0.0969 | 1 | 0.7555
Random | Obs | 2 | 0.3999 | 0.0989 | 1.6169 | -1.2859 | 0.1985 | - | - | -
Fixed | RCTs | 34 | 0.5646 | 0.4526 | 0.7044 | -5.0639 | 0.0000 | 28.5308 | 33 | 0.6893
Random | RCTs | 34 | 0.5646 | 0.4526 | 0.7044 | -5.0639 | 0.0000 | - | - | -

CI = confidence interval; df = degrees of freedom; OR = odds ratio; Obs = observational studies; RCTs = randomized controlled trials

The results for the random-effects analysis of RCTs are shown in Figure 9.

Figure 9 Random-effects analysis of RCTs for withdrawals due to adverse events (ARBs vs. ACEIs)

Figure 9 displays a forest plot of RCT studies reporting the odds ratio for withdrawals due to adverse events, ARBs versus ACEIs. In the 34 studies, the combined estimated odds ratio was 0.565 (95% CI 0.453 to 0.704), suggesting that the odds of withdrawing due to an adverse event are only 56 percent as large with an ARB as with an ACEI.

The results are best summarized by the random-effects analysis of the RCTs. This analysis gave an estimated odds ratio of 0.565 (95% CI 0.453 to 0.704), suggesting that the odds of withdrawing due to an adverse event are only 56 percent as large with an ARB as with an ACEI.

These odds ratios need to be compared against the overall withdrawal rate for ACEIs. If we pool all of the RCTs, we get a rate of about 5.4 percent.

There were two studies (both RCTs) comparing a direct rennin inhibitor with an ACEI. Their results are summarized in Table 23.

Table 23 Meta-analyses of withdrawals due to adverse events for direct renin inhibitors vs. ACEIs

Model | Analysis subgroup | No. of studies | OR estimate | 95% CI lower limit | 95% CI upper limit | Z value | P value | Q value | df (Q) | P value
Fixed | RCTs | 2 | 0.8282 | 0.5747 | 1.1935 | -1.0113 | 0.3119 | 2.9951 | 1 | 0.0835
Random | RCTs | 2 | 0.8861 | 0.4581 | 1.7136 | -0.3595 | 0.7193 | - | - | -

CI = confidence interval; df = degrees of freedom; OR = odds ratio; RCTs = randomized controlled trials

This analysis gave an estimated odds ratio of 0.886 (95% CI of 0.458, 1.714), suggesting that the estimated odds of withdrawing due to adverse events is only 89 percent as large with a direct renin inhibitor as it is with an ACEI, but this value is not significantly different from 1.00 (100 percent).

Caveats and concerns in relation to these data include the fact that only 9 of the 40 studies were considered to be of good methodological quality. Also, there was significant heterogeneity in the reporting of withdrawal data. Many studies reported limited data on withdrawal rates. Moreover, only one trial analyzed data to assess variation in withdrawal rates by specific demographic subgroups.117

### Adherence and Persistence

Forty-one papers describing 39 distinct studies reported at least some quantitative information on persistence or adherence24,25,28,33-35,40,42,47,49,50,52,57,58,62,70,71,73,78,89,100,101,103,105-108,114,118-130 Studies of adherence consisted of RCTs that assessed reported pill counts or subject dropout. Since subject dropout did not uniformly reflect adherence with medication (as opposed to adherence with the study protocol, for example), we focused on the nine studies that measured pill counts. Seventeen studies of persistence – whether patients remain on the initial ACEI, ARB, or direct renin inhibitor – included 4 RCTs as well as 13 longitudinal cohorts in which patients were followed in a real-world setting. Two studies evaluated adherence to an ACEI versus a direct renin inhibitor, and one evaluated adherence to an ARB versus a direct renin inhibitor. All the other studies compared ACEIs to ARBs. While adherence and persistence were lower in cohort studies than in the randomized trials, the general conclusions from the two groups of studies were similar.

With the possible exception of the study by Koylan et al.,89 adherence with ACEIs and ARBs was similar (Table 24). Moreover, adherence was high: above 90 percent in all studies, and at least 97 percent in five of the nine studies assessed. Most studies appeared to define adherence as the percentage of patients taking approximately 100 percent of the prescribed pills, although not every article was precise in reporting how this figure was derived. The absolute magnitude of adherence depended on the width of the acceptable range (e.g., McInnes et al.58 used a narrow range of 90 to 110 percent of prescribed pills and so might be expected to report lower adherence than Malmqvist et al.,57 which considered a wider range of 75 to 125 percent of prescribed pills to be acceptable). Also, randomized trials, which engender such biases as motivated volunteers and a Hawthorne effect, will tend to overestimate adherence in comparison with usual practice. Nevertheless, the overall conclusion that adherence was good and similar between ACEIs and ARBs seems well supported.

Table 24 Studies of treatment adherence with ACEIs and ARBs

Study | Adherence with ACEIs | Adherence with ARBs | Definition of adherence
Amerena et al., 2002^35^ | 99% | 99% | Pill counts at 6 weeks
Amerena et al., 2002^35^ | 98% | 98% | Pill counts at 12 weeks
Coca et al., 2002^40^ | 98.4% | 98.3% | Taking 80-110% of pills
Fogari et al., 2006^47^ | 92% | 94% | Pill count at each study visit
Koylan et al., 2005^89^ | ~ 94% | ~ 96% | Taking pills daily at 1 month visit
Koylan et al., 2005^89^ | ~ 86% | ~ 96% | Taking pills daily at 3 month visit
Koylan et al., 2005^89^ | ~ 87% | ~ 96% | Taking pills daily at 6 month visit
Malmqvist et al., 2000^57^ | > 98% | > 98% | Taking 75-125% of pills at 6 weeks
Malmqvist et al., 2000^57^ | > 98% | > 98% | Taking 75-125% of pills at 12 weeks
McInnes et al., 2000^58^ | 90% | 90% | Taking 90-110% of pills
Rosei et al., 2005^70^ | 98.2% | 97.8% | Not specifically defined
Tedesco et al., 2006^34^ | > 90% | > 90% | Pill count at study visits
Williams et al., 2006^108^ | > 98.8% | > 98.8% | Taking 80-120% of pills

Regarding persistence, the majority of evidence came from nonexperimental studies, which are subject to a variety of caveats, described below. These caveats notwithstanding, the results were quite consistent in that persistence with ARBs was modestly better than persistence with ACEIs (Table 25). Noting both the consistency of this finding across studies and the rather modest degree of differences in persistence, the conclusion that ARBs exhibit somewhat better persistence than ACEIs can be drawn with a moderate degree of confidence. No study reported persistence associated with direct renin inhibitor treatment.

Table 25 Studies of persistence with ACEIs and ARBs

Study | Duration | ACEIs | | | ARBs
Study | Duration
Study | Duration | Continued | Switched | Discontinued | Continued | Switched | Discontinued
Randomized trials
Saito et al., 2004^71^ | 6 mo | 71% | 28% | 2% | 89% | 9% | 2%
Koylan et al., 2005^89^ | 6 mo | ~ 82% | - | - | ~ 89% | - | -
Hosohata et al., 2007^50^ | 12 mo | 55% | - | - | 88% | - | -
Veronesi et al.,2007^100^ | 24 mo | 61.5% | - | - | 68.5% | - | -
Longitudinal cohort studies
Hasford et al., 2002^49^ | 1 yr | 42% | - | - | 44.7 to 60.8% | - | -
Mazzaglia et al., 2005^114^ | 1 yr | ~ 50% | ~ 8% | ~ 42% | ~ 50% | ~ 10% | ~ 40%
Bloom et al., 1998^118^/Conlin et al., 2001^121^ | 1 yr | 58% | 9% | 33% | 64% | 7% | 29%
Bloom et al., 1998^118^/Conlin et al., 2001^121^
Bloom et al., 1998^118^/Conlin et al., 2001^121^ | 4 yr | 46.5% | 18.9% | 34.6% | 50.8% | 16.5% | 32.7%
Erkens et al., 2005^124^ | 1 yr | 59.7% | - | - | 62.0% | - | -
Marentette et al., 2002^125^ | 1 yr | - | - | ~ 35% | - | - | ~ 15%
Bourgault et al., 2005^119^ | 1 yr | - | - | 41% | - | - | 34%
Bourgault et al., 2005^119^
Bourgault et al., 2005^119^ | 2 yr | - | - | 53% | - | - | 44%
Bourgault et al., 2005^119^
Bourgault et al., 2005^119^ | 3 yr | - | - | 60% | - | - | 47%
Burke et al., 2006^120^ | 1 yr | - | - | 37.8% | - | - | 29.4%
Burke et al., 2006^120^
Burke et al., 2006^120^ | 2 yr | - | - | 48.0% | - | - | 41.3%
Burke et al., 2006^120^
Burke et al., 2006^120^ | 3 yr | - | - | 54.8% | - | - | 50.3%
Burke et al., 2006^120^
Burke et al., 2006^120^ | 4 yr | - | - | 60.4% | - | - | 57.8%
Wogen et al., 2003^126^ | 1 yr | 50% | - | - | 63% | - | -
Degli Esposti et al., 2002^122,123^ | 1 yr | 30.7% | 9.4% | 59.9% | 33.4% | 24.6% | 42.0%
Hasford et al., 2007^127^ | 1 yr | 28.2% | - | - | 26.4% | - | -
Hasford et al., 2007^127^ | 2 yr | 18.6% | - | - | 15.3% | - | -
Hasford et al., 2007^127^ | 3 yr | 14.0% | - | - | 10.6% | - | -
Patel et al., 2007^129^ | 1 yr | 48.0% | - | - | 51.9% | - | -
Lachaine et al., 2008^128^ | 2 yr | 58.9% | - | - | 60.9% | - | -
Simons et al., 2008^130^ | 33 mo | 45% (95% CI 44 to 46%) | - | - | 47% (95% CI 46 to 48%) | - | -

The results of the longitudinal studies should be considered in light of several caveats. The longitudinal cohort studies typically use administrative databases and, even though investigators control for differing patient characteristics as much as possible, this design cannot assure that patients receiving different medications are similar, even after statistical adjustment. Consequently, the consistency of results across multiple studies is crucial. Results of multi-predictor analyses, when present, yielded substantially similar conclusions to the simple comparison of unadjusted persistence provided above; accordingly, we focus on the unadjusted results.

The ideal outcome would disaggregate patients into four mutually exclusive and exhaustive categories: (1) continued initial medication without change; (2) continued initial medication but added another medication from a different class; (3) changed to another medication from a different class; and (4) discontinued medication entirely. Almost all of the reports aggregated the first two categories, which we have combined throughout. Within each category, definitions are not entirely consistent, but are close enough for purposes of comparison.

As a final caveat, several of the longitudinal cohort studies (e.g., Marentette et al.,125 Bourgault et al.,119 Burke et al.,120 Wogen et al.,126 and Degli Esposti et al.122,123) corresponded in time to the introduction of ARBs, and thus have relatively small sample sizes for this class of medication. Accordingly, for these studies persistence is estimated with less precision than might be desired.

## Key Question 3 Are there subgroups of patients—based on demographic and other characteristics (i.e., age, race, ethnicity, sex, comorbidities, concurrent us of other medications)—for whom ACEIs, ARBs, or direct renin inhibitors are more effective, are associated with fewer adverse events, or are better tolerated?

### Key Points

- Evidence does not support conclusions regarding the comparative effectiveness, adverse events, or tolerability of ACEIs, ARBs, and direct renin inhibitors for any particular patient subgroup.

### Blood Pressure

#### Comparisons of ACEIs Versus ARBs

We did not identify any subgroup of patients in whom one ACEI or ARB was clearly superior. Two of 78 studies reporting blood pressure outcomes included only women,46,57 and 2 additional studies reported results for a female subgroup.51,56 Three of these four found no significant difference in blood pressure effects between the ACEI and the ARB treatment arms; however, the largest of the four57 reported superior blood pressure lowering in the ARB arm compared to the ACEI (n = 286, mean between group difference 5.5/2.2 mm Hg; p ≤ 0.01). There were five studies conducted exclusively in elderly patients (age ≥ 65), and three additional studies that reported separate results for this age group.27,30,36,45,51,56,76,84 Five of these studies showed no difference between ACEI and ARB treatment in elderly patients,30,36,51,56,84 and the remaining three studies reported better blood pressure lowering in the ARB arm.27,45,76 Ten studies were conducted only in diabetic patients with hypertension, none of which showed a difference between the two classes of medication.23,32,37,44,52,53,60,70,83,88 In four studies, blood pressure was reported as an outcome in a subgroup of black patients.29,55,61,76 Three of these studies found no difference in the efficacy of ACEIs versus ARBs in black patients, while one reported significantly better DBP lowering in ARB-treated patients compared to ACEI-treated patients.76

#### Comparisons of Direct Renin Inhibitors Versus ACEIs or ARBs

Of the three studies comparing the direct renin inhibitor aliskiren to an ACEI or ARB, one was conducted solely in patients over age 65.^105^ Aliskiren provided greater blood pressure lowering than the ACEI ramipril; however, this result was also reported in a similar study comparing aliskiren and ramipril, which was not restricted to patients over age 65 (two publications103,104), suggesting that this effect is unlikely to be unique to an elderly subgroup.

#### Mortality and Major Cardiovascular Events

Because of scant data on mortality, MI, and stroke, it was not possible to assess whether ACEIs and ARBs have any differential effect on event rates in any subgroups of patients based on demographic characteristics, use of other medications concurrently, or comorbidities.

#### Quality of Life

None of the included trials reported any differential impact of ACEIs versus ARBs (or versus direct renin inhibitors) on quality-of-life measures by clinically relevant subgroup.

#### Safety and Adverse Events

In general, there is no evidence supporting differential rates of adverse events for ACEIs versus ARBs or direct renin inhibitors with regard to any specific subgroup. However, one study included only women in the study population.57 The overall rates of cough reported by the study were similar to those reported by other studies that included men and women. One study reported results for a female subgroup.117 The proportion of women in the latter study was 55.7 percent, and rates of cough in this study were higher for women treated with ACEIs (statistically significant for two of the three ACEIs studied in the trial) than they were for women treated with ARBs.

Prior studies not included in this review have reported a relative risk of angioedema of approximately 3 to 4 for African-Americans treated with an ACEI versus Caucasians treated with an ACEI.131,132 In the studies we reviewed for the present report, rates of angioedema were too low to confirm this finding for ACEIs or to identify any subgroup differences across the three different medication classes.

#### Adherence and Persistence

There is not sufficient evidence that particular patient subgroups are more or less likely to be persistent in taking an ACEI versus an ARB, and we did not identify any studies on persistence that included patients taking a direct renin inhibitor. However, some observations emerge regarding persistence with ACEIs or ARBs (Table 26). The most consistent result is that persistence increased with age: patients in the 65- to 84-year-old age range tended to exhibit the highest persistence of all. The contribution of sex was inconsistent. There is some evidence that a history of cardiovascular disease is associated with greater persistence, a possible explanation being that such a history could make hypertension management more salient to the patient.

Table 26 Predictors of persistence with ACEIs and ARBs

Study | Predictors of persistence
Mazzaglia et al., 2005^114^ | Increasing age, family history of cardiovascular diseases and diabetes, no severe hypertension, low chronic disease score
Bloom et al., 1998^118^ (1yr)/Conlin et al., 2001^121^ (4 yr) | 1 yr: Increasing age, < 1 dose per day, male sex 4 yr: Increasing age, female sex
Erkens et al., 2005^124^ | Increasing age, male sex, antidiabetic drugs, lipid lowering drugs, previous cardiovascular hospitalizations
Marentette et al., 2002^125^ | Increasing age, female sex
Degli Esposti et al.,2002^123^ (1 yr)/Degli Esposti et al., 2002^122^ (3 yr) | 1 yr: Increasing age, medications for heart disease or diabetes, previous cardiovascular hospitalizations, ≥ 2 comorbidities 3 yr: Increasing age, male sex, younger general practitioner, male sex of general practitioner
Simons et al. , 2008^130^ | Age < 40 years associated with lowest persistence (16% persistence, and 3 months median persistence time) Age 60-69 years associated with highest persistence (50% persistence, and 33 months median persistence time) No significant difference by sex

#### Lipids

Several potentially relevant subgroups were identified, but none had a clear difference between the compared medications in lipid parameter outcomes. Six studies evaluated patients with diabetes.23,32,44,53,60,88 These included three that found small changes in various lipid parameters,23,53,88 but the other three found none.32,44,60 Another study examined patients with hypertension and components of the metabolic syndrome (at least two of: high triglycerides, low HDL, high blood glucose, or high waist circumference); it found improvements in TC, TG, HDL, and LDL for ramipril and valsartan, but no differences between the medications.102 One study targeting postmenopausal women,46 one taking place in Japan,77 and two taking place in Turkey73,88 did not have detectable changes in the lipid profile. Another study taking place in Turkey102 found improvement in all lipid parameters with both ramipril and valsartan, while another study taking place in China101 found greater improvements in TG and HDL with telmisartan than with enalapril.

#### Diabetes Markers

In the eight studies requiring diabetes as an inclusion criteria, six found no difference in individuals receiving ACEIs or ARBs in glucose or HbA1c levels;32,44,60,73,88,113 one found no change in glucose but a small statistically significant increase in HbA1c for the ARB (+ 0.25 percent enalapril, + 0.6 percent losartan; data not reported for between-group comparisons);53 and one found no change in HbA1c but a decline in glucose levels for both which was statistically greater for the ACEI when measured at 12 months (perindopril -15 ± 4 mg/dL, candesartan -8 ± 2 mg/dL).23 Thus, for the two studies for which a difference was found, the difference was discrepant (i.e., an increase in HbA1c in one and a decline in glucose in the other), and only one directly analyzed differences between the two groups.

In addition to studies of individuals with diabetes, measures of glucose or HbA1c were performed for several other subgroups including Asians,62,77,96,101 Turks,73,88,102,113 Brazilians,80 Portuguese,110 Spaniards,25 Argentineans,72 Czechs,98 and postmenopausal women.46 None of these studies identified a difference in the impact of ACEIs and ARBs with regard to fasting glucose or HbA1c.

#### LV Mass/Function

Although 10 of the 13 studies that presented results on LV mass or function demonstrated some decreases in LVMI (or equivalent measure), the sum of the evidence does not demonstrate a difference between ACEIs, ARBs, and direct renin inhibitors with regard to their effect on LV mass or function for individuals with essential hypertension. No subgroup analyses were performed by study investigators to help identify subgroups of patients who were more likely to have improvements in LV mass or function in any of the studies.

#### GFR/Proteinuria

There are no consistently demonstrated differential effects with use of ACEIs, ARBs, or direct renin inhibitors related to either renal function (as measured by creatinine or GFR) or reduction of urinary protein or albumin excretion. As a result, we were not able to identify subgroups of patients for whom either ACEIs or ARBs are more effective in preserving renal function or decreasing urinary protein or albumin excretion, or are better tolerated without causing sustained elevations in serum creatinine.