# Peer Reviewers

Thomas Lumley, Ph.D.

University of Chicago

Chicago, IL

Suzanne Oparil, M.D.

University of Alabama at Birmingham

Birmingham, AL

Nirav Shah, M.D., M.P.H.

Geisinger Health Systems

Danville, PA

C. Michael White, Pharm.D.

University of Connecticut

Storrs, CT