# Methods

## Topic Development

The topic for the original 2007 report12 was nominated in a public process. With input from technical experts, the Scientific Resource Center (SRC) for the Agency for Healthcare Research and Quality (AHRQ) Effective Health Care Program drafted the initial Key Questions for that report and, after approval from AHRQ, posted them to a public Web site. The public was invited to comment on these questions. After reviewing the public commentary, the SRC drafted final Key Questions and submitted them to AHRQ for approval.

For the present updated report, AHRQ initially proposed the same scope and Key Questions. In response to input from the project's technical expert panel, the Key Questions were modified to include the comparative risks and benefits of direct renin inhibitors. The revised Key Questions were then posted to a public Web site for comment and were modified again in response to the comments received.

## Search Strategy

We conducted a comprehensive search of the scientific literature to identify systematic reviews, randomized controlled trials, and nonrandomized comparative studies relevant to the Key Questions. Searches of electronic databases used the National Library of Medicine's Medical Subject Headings (MeSH) keyword nomenclature developed for MEDLINE and adapted for use in other databases. Searches included terms for drug interventions, hypertension, and study design, and were limited to studies published in English after 1988. The texts of the major search strategies are given in Appendix A. We also reviewed selected gray literature (e.g., regulatory data, clinical trial registries and conference abstracts) received from the SRC, the reference lists of relevant review articles, and citations identified by peer and public reviewers of the draft report. Gray literature is defined as “that which is produced on all levels of government, academics, business and industry in print and electronic formats, but which is not controlled by commercial publishers.”14 We did not undertake a systematic search for unpublished data.

To identify literature describing direct comparisons of angiotensin-converting enzyme inhibitor(s) (ACEIs), angiotensin II receptor blocker(s)/antagonist(s) (ARBs), or direct renin inhibitors we searched:

- MEDLINE (1966 to December 23, 2010);
- Embase (all years, ending on December 23, 2010);
- The Cochrane Central Register of Controlled Trials (Issue 2, 2006; not updated thereafter);
- A register of systematic reviews underway in the Cochrane Hypertension Review Group (December 1, 2010); and
- Gray literature identified by the SRC (last search date December 30, 2009).

Table 2 lists the types and sources of gray literature searched by the SRC:

Table 2 Types and sources of gray literature searched

Type of source | Specific sources searched
Regulatory information | FDA Health Canada Authorized Medicines for EU
Clinical trial registries | ClinicalTrials.gov Current Controlled Trials Clinical Study Results WHO Clinical Trials
Abstracts and conference papers | Conference Papers Index Scopus
Grants and federally funded research | NIH RePORTER (a searchable database of federally funded biomedical research projects conducted at universities, hospitals, and other research institutions) HSRPROJ (a database providing access to ongoing grants and contracts in health services research)
Other miscellaneous sources | Hayes, Inc. Health Technology Assessment NY Academy of Medicine's Grey Literature Index

EU = European Union; FDA = U.S. Food and Drug Administration; NIH = National Institutes of Health; NY = New York; WHO = World Health Organization

In our original report, we conducted additional searches in MEDLINE for studies of ARBs versus other (non-ACEI) comparators and ACEIs versus other (non-ARB) comparators for potential use in the event that evidence from direct head-to-head trials proved to be insufficient for some or all of the outcomes of interest in the review. The process used to screen this literature and evaluate its relevance is described in Appendix B. Because we did not use the evidence from these indirect comparisons in our original report, we eliminated this step in the current update and did not search for or include such indirect comparison studies.

Our searches identified a total of 2090 citations. We imported all citations into an electronic database (EndNote version X4).

## Study Selection

We developed criteria for inclusion and exclusion based on the patient populations, interventions, and outcome measures specified in the Key Questions. The abstract screening criteria we used (Appendix C) were designed to identify only relevant direct head-to-head comparator studies (ACEIs vs. ARBs, ACEIs vs. direct renin inhibitors, or ARBs vs. direct renin inhibitors). We retrieved the full text of all potentially relevant articles for further review. We then applied a second, more stringent set of criteria for inclusion and exclusion (Appendix C).

The remainder of this section describes in greater detail the criteria we used to screen the available literature.

### Population and Condition of Interest

As specified in the Key Questions, this review focused on adult patients (age 18 years or older) with essential hypertension, as defined by study authors. We included studies with patients of mixed ages and mixed diagnoses only if results were reported separately for the relevant subgroups.

### Interventions and Comparators of Interest

We included the ACEIs, ARBs, and direct renin inhibitors listed in Table 1. In addition to straightforward comparisons of a single ACEI versus a single ARB or direct renin inhibitor, we also included “grouped” comparisons (e.g., a specific ARB vs. “ACEIs” or unspecified “ARBs” vs. unspecified “ACEIs”) and comparisons of an ACEI + drug X versus an ARB + drug X (e.g., losartan + hydrochlorothiazide [HCTZ] versus enalapril + HCTZ). We excluded comparisons of an ACEI + drug X versus an ARB + drug Y (e.g., enalapril + manidipine vs. irbesartan + HCTZ).

Studies with treatment protocols that permitted the addition of other antihypertensive medications during the trial if certain blood pressure targets were not met were included provided the cointervention protocols were the same in both groups.

### Outcomes of Interest

We considered a wide range of outcomes pertaining to the long-term benefits and harms of ACEIs, ARBs, or direct renin inhibitors. These are listed above in the section on “Scope and Key Questions.” In order of relative priority, these outcomes were:

Primary outcomes:

- Blood pressure control (we preferred seated trough blood pressure, where reported).
- Mortality (all-cause, cardiovascular disease-specific, and cerebrovascular disease-specific).
- Morbidity (especially major cardiovascular events [myocardial infarction (MI), stroke] and measures of quality of life).
- Safety (focusing on serious adverse event rates, overall adverse event rates, withdrawals due to adverse events, withdrawal rates, and switch rates).
- Specific adverse events (including, but not limited to, weight gain, impaired renal function, angioedema, cough, and hyperkalemia).
- Persistence/adherence.
- Rate of use of a single antihypertensive medication for blood pressure control.

Secondary outcomes:

- Lipid levels (high-density lipoprotein, low-density lipoprotein, total cholesterol, and triglycerides).
- Rates of progression to type 2 diabetes.
- Markers of carbohydrate metabolism/diabetes control (glycated hemoglobin [HbA1c], dosage of insulin or other diabetes medication, fasting plasma glucose, or aggregated measures of serial glucose measurements).
- Measures of left ventricular mass/function (left ventricular mass index [LVMI] and ejection fraction [LVEF]).
- Measures of kidney disease (creatinine/glomerular filtration rate [GFR], proteinuria).

### Timing

The Key Questions ask about the comparative long-term benefits and harms of ACEIs, ARBs, or direct renin inhibitors for treating essential hypertension, but do not define precisely what is meant by “long-term.” Some of our outcomes of interest, such as blood pressure lowering or medication side effects, could reasonably be assessed in a short timeframe, while many others (e.g., persistence, mortality, morbidity) may require years of followup. To include a broad range of studies reporting on our multiple outcomes, we opted to include studies with a minimum of 12 weeks of followup.

### Setting

We did not restrict the setting of the studies evaluated in our analysis.

### Types of Studies

We included comparative clinical studies of any design, including randomized controlled trials (RCTs), nonrandomized controlled clinical trials, retrospective and prospective cohort studies, and case-control studies.

## Analytic Framework

Figure 1 depicts the Key Questions within the context of the population, interventions, comparators of interest, outcomes, timing, and settings (PICOTS) described in the previous section. In general, the figure illustrates how ACEIs, ARBs, and direct renin inhibitors affect (1) measures of blood pressure control, lipid levels, carbohydrate metabolism/diabetes control, measures of LV mass/function, or measures of kidney disease (creatinine/GFR, proteinuria); and/or (2) clinically significant outcomes, such as mortality (all-cause, cardiovascular disease-specific, and cerebrovascular disease-specific) or morbidity (especially major cardiovascular events [MI, stroke], rates of progression to type 2 diabetes, and measures of quality of life). In addition, adverse events (including, but not limited to, weight gain, impaired renal function, angioedema, cough, and hyperkalemia) may occur at any point after ACEIs, ARBs, and/or direct renin inhibitors are received.

Figure 1 Analytic framework

ACEI = angiotensin-converting enzyme inhibitor; ARB = angiotensin II receptor blocker(s)/antagonist(s); GFR = creatinine/glomerular filtration rate; LV = left ventricular; MI = myocardial infarction

Figure 1 depicts the key questions within the context of the population, interventions, comparators of interest, outcomes, timing, and settings (PICOTS) described in the previous section. In general, the figure illustrates how ACEIs, ARBs, and direct renin inhibitors affect (1) measures of blood pressure control, lipid levels, carbohydrate metabolism/diabetes control, measures of left ventricular mass/function, or measures of kidney disease (creatinine/GFR, proteinuria); and/or (2) clinically significant outcomes, such as mortality (all-cause, cardiovascular disease-specific, and cerebrovascular disease-specific) or morbidity (especially major cardiovascular events [myocardial infarction, stroke], rates of progression to type 2 diabetes, and measures of quality of life). In addition, adverse events (including, but not limited to, weight gain, impaired renal function, angioedema, cough, and hyperkalemia) may occur at any point after ACEIs, ARBs, and/or direct renin inhibitors are received.

## Data Extraction

We developed a data abstraction form/evidence table template for abstracting data from the included studies (Appendix D) and used the same form for all study designs and to capture data relevant to all three Key Questions. Abstractors worked in pairs: the first abstracted the data, and the second over-read the article and the accompanying abstraction to check for accuracy and completeness. The completed evidence table, including a row for each study, is provided in Appendix E.

We extracted the following data: geographical location; funding source; study design; interventions (including dose, duration, dose titration protocol [if any], and cointerventions [if any]); population characteristics (including age, sex, race/ethnicity, baseline blood pressure, concurrent medications, and comorbidities); recruitment setting; inclusion and exclusion criteria; numbers screened, eligible, enrolled, and lost to followup; and results for each outcome.

## Quality Assessment

We used predefined criteria to assess the quality of individual controlled trials and prospective or retrospective observational (cohort) studies. To assess the quality of clinical trials and cohort studies, we adapted criteria developed by the U.S. Preventive Services Task Force (USPSTF) and the Centre for Reviews and Dissemination (CRD).15,16 The approach used is similar to that now recommended in AHRQ's Methods Guide for Effectiveness and Comparative Effectiveness Reviews.17

Individual studies were graded as “good,” “fair,” or “poor” in quality according to the following definitions:

- A “good” study has the least bias and results are considered valid. A good study has a clear description of the population, setting, interventions, and comparison groups; uses a valid approach to allocate patients to alternative treatments; has a low dropout rate; and uses appropriate means to prevent bias, measure outcomes, and analyze and report results.
- A “fair” study is susceptible to some bias, but probably not sufficient to invalidate the results. The study may be missing information, making it difficult to assess limitations and potential problems. As the fair-quality category is broad, studies with this rating vary in their strengths and weaknesses. The results of some fair-quality studies are possibly valid, while others are probably valid.
- A “poor” rating indicates significant bias that may invalidate the results. These studies have serious errors in design, analysis, or reporting; have large amounts of missing information; or have discrepancies in reporting. The results of a poor-quality study are at least as likely to reflect flaws in the study design as to indicate true differences between the compared interventions.

If a study was rated as fair or poor, assessors were instructed to note important limitations on internal validity based on the USPSTF/CRD criteria, as adapted here:

1. Initial assembly of comparable groups:
2. a. For RCTs: Adequate randomization, including concealment and whether potential confounders were distributed equally among groups.
  b. For cohort studies: Consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts.
3. Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination).
4. Important differential loss to followup or overall high loss to followup.
5. Measurements: Equal, reliable, and valid (includes masking of outcome assessment).
6. Clear definition of interventions.
7. All important outcomes considered.
8. Analysis: Adjustment for potential confounders for cohort studies, or intention-to-treat analysis for RCTs.

Assessment of each study's quality was made by a single rater and then evaluated by a second rater. Finally, quality assessments were reviewed across studies. Disagreements were resolved by consensus. Final quality assessments for individual studies are included in the evidence table (Appendix E).

## Applicability

We did not provide a global rating of applicability (such as “high” or “low”) because applicability may differ substantially based on the user of this report. However, applicability of research studies was assessed by noting the most important potential limitations in a study's applicability from among the list described by Rothwell.18 These criteria, slightly adapted by the SRC for the original 2007 report, are reproduced in Appendix F. Assessors were instructed to list the most important (up to three) limitations affecting applicability, if any, based on this list. The approach used is broadly similar to that now recommended in AHRQ's Methods Guide for Effectiveness and Comparative Effectiveness Reviews.19

Throughout this report, we highlight effectiveness studies conducted in primary care or office-based settings that use less stringent eligibility criteria, assess health outcomes, and have longer followup periods than most efficacy studies. The results of effectiveness studies are more applicable to the spectrum of patients that will use a drug, have a test, or undergo a procedure than results from highly selected populations in efficacy studies.

We chose to include observational designs because these studies may be more likely to reflect the broadest spectrum of patients in typical clinical settings and therefore provide complementary information not adequately captured in clinical trials. Observational studies, however, are prone to significant selection bias and residual confounding and may therefore result in biased estimates of treatment effect. In particular, patients treated with an ARB or direct renin inhibitor may be more likely to have experienced intolerance to an ACEI, or could differ in other important ways associated with cost differences across the medication classes. To address this, we performed separate meta-analyses for RCTs and observational studies so that treatment effects could be estimated without the biases introduced by observational designs.

## Rating the Body of Evidence

For the present update, we assessed the strength of the body of evidence for each Key Question using the approach recommended in AHRQ's Methods Guide for Effectiveness and Comparative Effectiveness Reviews.20 This approach is conceptually similar to the GRADE (Grading of Recommendations Assessment, Development, and Evaluation) framework21 used in the 2007 report. In rating the strength of evidence, we considered the number of studies, the size of the studies, strength of study design, and the quality of individual studies. We also assessed risk of bias, directness, precision, consistency across studies of the same design, consistency across different study designs, magnitude of effect, applicability, and the potential for publication bias. Finally, if applicable, we considered (especially for observational studies) the potential influence of plausible confounders. We commented specifically when it was difficult or impossible to assess certain of these dimensions. The overall strength of a given body of evidence was rated qualitatively using the following four-level scale:

- High—High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
- Moderate—Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
- Low—Low confidence that the evidence reflects the true effect. Further research is likely to change the confidence in the estimate of effect and is likely to change the estimate.
- Insufficient—Evidence is either unavailable or does not permit estimation of an effect.

## Data Synthesis

Given that many studies did not have the statistical power to determine equivalence for the outcomes relevant to this review (which were often not the primary outcomes evaluated by study investigators), we considered synthesis (meta-analysis) in an attempt to overcome the type II error.

In evaluating groups of studies reporting the same or similar outcomes for potential data synthesis, we primarily considered clinical diversity. In this assessment, we tended to be inclusive of individual studies unless their populations were clearly dissimilar (e.g., when considering renal outcomes we chose to exclude from pooled analysis studies of patients with renal failure). We considered groups of studies to be suitable candidates for a quantitative synthesis when we were able to identify at least four clinically relatively similar studies that assessed the same outcome (e.g., when considering effects on lipids, we chose not to pool, as the group included different lipid measures.) While not proof of the validity of this approach, it is notable that there were no situations in which pooled estimates of relative efficacy regarding a particular outcome were contrary to the global impression of the reviewers.

When we calculated summary effect sizes, we stratified these by study design, separating RCTs from observational studies. We used Comprehensive Meta-Analysis Version 2 (Borenstein M, Hedges L, Higgins J, Rothstein H. Comprehensive Meta-Analysis Version 2, Biostat, Englewood NJ [2005]) to synthesize the available evidence. We used Begg's test to assess heterogeneity, while recognizing that the ability of statistical methods to detect heterogeneity is limited, particularly when the number of studies is small. In the presence of statistical heterogeneity, we evaluated study design characteristics to determine whether they could explain the heterogeneity observed. To allow for the presence of statistical heterogeneity, we used random-effects models. Meta-analyses combining both study designs were also calculated in order to estimate confidence limits for an overall effect.

When meta-analysis was performed, we used the random-effects model for the primary analysis; in addition, we present summary estimates derived using the fixed-effect model as a sensitivity analysis. Furthermore, for dichotomous outcomes, we used the odds ratio as the effect measure. This was done because it resulted in less heterogeneity than did risk differences.

We attempted to conform as closely as possible to the recommendations on performing meta-analyses in AHRQ's Methods Guide for Effectiveness and Comparative Effectiveness Reviews.22 We combined dichotomous events using odds ratios and continuous measures using differences in means. Because of the natural heterogeneity of the studies, we primarily reported the results of random-effects models as calculated by Comprehensive Meta-Analysis. We checked for publication bias using funnel plots and Begg and Mazumdar's correlation test for publication bias. We calculated the Q statistic as a measure of heterogeneity, but this was descriptive information, as we expect some heterogeneity in the studies. For reporting the meta-analyses, we attempted to conform as closely as possible to the PRISMA guidelines (www.prisma-statement.org).

Given the dearth of studies of the same ACEI versus ARB comparison and the presumed general similarity of each class, when studies were combined, pooling was performed without regard to the specific drug within the ACEI or ARB class. We stratified the analysis to examine differences between observational studies and RCTs, as described above.