# Analyses of Potential Publication Bias

We used Comprehensive Meta-Analysis Version 2 (Borenstein M, Hedges L, Higgins J, Rothstein H. Comprehensive Meta-analysis Version 2, Biostat, Englewood NJ [2005]) to test for potential publication bias for the outcomes described below.

## Diastolic Blood Pressure Reduction

We used Comprehensive Meta-Analysis to examine any potential publication bias in the studies of diastolic blood pressure reduction. The resulting funnel plot is shown in Figure H1.

Figure H1 Funnel plot for studies of diastolic blood pressure reduction

Figure H1 displays a funnel plot for studies of diastolic blood pressure reduction to explore the potential for publication bias. There is no asymmetry in the plot. Six studies lie to the left of the funnel, and five or six studies lie to the right. The correlation was 0.0369 (two-tailed p-value = 0.7914). Thus there was no evidence of publication bias in this meta-analysis.

Note that there is no asymmetry in the plot. Six studies lie to the left of the funnel, and five or six studies lie to the right. The software computed Begg and Mazumdar's correlation test for publication bias. The correlation was 0.0369 (two-tailed p-value = 0.7914). Thus there was no evidence of publication bias in this meta-analysis.

## Cough In Trials Studying Diastolic Blood Pressure Reduction

We used Comprehensive Meta-Analysis to examine any potential publication bias in the RCT studies of cough in trials studying blood pressure control. The funnel plot for the studies is shown in Figure H2.

Figure H2 Funnel plot for RCTs of cough in trials studying blood pressure control

Figure H2 displays a funnel plot for RCT studies of cough to explore the potential for publication bias. There is no asymmetry in the plot. One of the studies lies to the left of the funnel and two of the studies lie to the right. The correlation was 0.000 (two-tailed p-value = 1.000). Thus there was absolutely no evidence of a publication bias in this meta-analysis.

Note that there is no asymmetry in the plot. One of the studies lies to the left of the funnel and two of the studies lie to the right. The software computed Begg and Mazumdar's correlation test for publication bias. The correlation was 0.000 (two-tailed p-value = 1.000). Thus there was absolutely no evidence of a publication bias in this meta-analysis.

## Withdrawals Due to Adverse Events

We used Comprehensive Meta-Analysis to examine any potential publication bias in studies reporting withdrawals due to adverse events. The funnel plot for the studies is shown in Figure H3.

Figure H3 Funnel plot for studies reporting withdrawals due to adverse events

Figure H3 displays a funnel plot for studies of withdrawals due to adverse events to explore the potential for publication bias. There is no asymmetry in the plot. Two of the studies lie to the left of the funnel, and none of the studies lies to the right. The correlation was -0.1113 (two-tailed p-value = 0.3404). There is no evidence of a publication bias in this meta-analysis.

Note that there is no asymmetry in the plot. Two of the studies lie to the left of the funnel, and none of the studies lies to the right. The software computed Begg and Mazumdar's correlation test for publication bias. The correlation was -0.1113 (two-tailed p-value = 0.3404). There is no evidence of a publication bias in this meta-analysis.