# List of Excluded Direct Comparator Studies

All studies listed below were either identified at the abstract screening stage as having treatment duration/length of followup less than 12 weeks or were reviewed in their full-text version and excluded. Following each reference, in italics, is the reason for exclusion. Reasons for exclusion signify only the usefulness of the articles for this study and are not intended as criticisms of the articles.

Akinboboye OO, Chou RL, Bergmann SR. Augmentation of myocardial blood flow in hypertensive heart disease by angiotensin antagonists: a comparison of lisinopril and losartan. J Am Coll Cardiol. 2002;40(4):703-9. Exclude: N < 20. [pmid: 12204500].
Ali K, Rajkumar C, Fantin F, et al. Irbesartan improves arterial compliance more than lisinopril. Vascular Health & Risk Management. 2009;5(4):587-92. Exclude: N < 20. [pmid: 19649309].
Alcocer L, Fernandez-Bonetti P, Campos E, et al. Clinical efficacy and safety of telmisartan 80 mg once daily compared with enalapril 20 mg once daily in patients with mild-to-moderate hypertension: results of a multicentre study. Int J Clin Pract Suppl. 2004;(145):23-8. Exclude: Followup < 12 wk. [pmid: 15617455].
Almazov VA, Shlyakhto EV, Konrady AO, et al. Correction of hypertensive cardiac remodelling: comparison of different antihypertensive therapies. Med Sci Monit. 2000;6(2):309-13. Exclude: N < 20. [pmid: 11208328].
Altiparmak MR, Trablus S, Apaydin S, et al. Is losartan as effective as enalapril on posttransplant persistent proteinuria?. Transplant Proc. 2001;33(7-8):3368-9. Exclude: Not essential hypertension. [pmid: 11750440].
Andersen S, Tarnow L, Rossing P, et al. Renoprotective effects of angiotensin II receptor blockade in type 1 diabetic patients with diabetic nephropathy. Kidney Int. 2000;57(2):601-6. Exclude: Followup < 12 wk. [pmid: 10652037].
Anderson RE, Pfeffer MA, Thune JJ, et al. High-risk myocardial infarction in the young: The VALsartan In Acute myocardial iNfarcTion (VALIANT) trial. American Heart Journal. 2008;155(4):706-711. Full Text: Exclude - HTN outcomes not reported separately. [pmid: 18371480].
Azizi M, Linhart A, Alexander J, et al. Pilot study of combined blockade of the renin-angiotensin system in essential hypertensive patients. J Hypertens. 2000;18(8):1139-47. Exclude: Followup < 12 wk. [pmid: 10954007].
Aznaouridis KA, Stamatelopoulos KS, Karatzis EN, et al. Acute effects of renin-angiotensin system blockade on arterial function in hypertensive patients. Journal of Human Hypertension. 2007;21(8):654-63. Full Text: Exclude - duration < 12 wks. [pmid: 17460710].
Bakris G, Sica D, Ram V, et al. A comparative trial of controlled-onset, extended-release verapamil, enalapril, and losartan on blood pressure and heart rate changes. Am J Hypertens. 2002;15(1 Pt 1):53-7. Exclude: Followup < 12 wk. [pmid: 11824861].
Bakris GL. ACE inhibitors and ARBs: are they better than other agents to slow nephropathy progression?. Journal of Clinical Hypertension. 2007;9(6):413-5. Full Text: Exclude - not a clinical trial. [pmid: 17541325].
Barnett A. Preventing renal complications in type 2 diabetes: Results of the diabetics exposed to telmisartan and enalapril trial. Journal of the American Society of Nephrology. 2006;17(SUPPL. 2):S132-S135. Full Text: Exclude - not a clinical trial. [pmid: 16565237].
Bavanandan S, Morad Z, Ismail O, et al. A comparison of valsartan and perindopril in the treatment of essential hypertension in the Malaysian population. Med J Malaysia. 2005;60(2):158-62. Exclude: Followup < 12 wk. [pmid: 16114156].
Benz J, Oshrain C, Henry D, et al. Valsartan, a new angiotensin II receptor antagonist: a double-blind study comparing the incidence of cough with lisinopril and hydrochlorothiazide. J Clin Pharmacol. 1997;37(2):101-7. Exclude: Followup < 12 wk. [pmid: 9055135].
Bohm M, Baumhakel M, Probstfield JL, et al. Sexual function, satisfaction, and association of erectile dysfunction with cardiovascular disease and risk factors in cardiovascular high-risk patients: Substudy of the ONgoing Telmisartan Alone and in Combination with Ramipril Global Endpoint Trial/Telmisartan Randomized AssessmeNT Study in ACE-INtolerant Subjects with Cardiovascular Disease (ONTARGET/TRANSCEND). American Heart Journal. 2007;154(1):94-101. Full Text: Exclude - HTN outcomes not reported separately. [pmid: 17584560].
Botero R, Matiz H, Maria E, et al. Efficacy and safety of valsartan compared with enalapril at different altitudes. Int J Cardiol. 2000;72(3):247-54. Exclude: Followup < 12 wk. [pmid: 10716135].
Brown NJ, Kumar S, Painter CA, et al. ACE inhibition versus angiotensin type 1 receptor antagonism: differential effects on PAI-1 over time. Hypertension. 2002;40(6):859-65. Exclude: Followup < 12 wk. [pmid: 12468570].
Byyny RL, Merrill DD, Bradstreet TE, et al. An inpatient trial of the safety and efficacy of losartan compared with placebo and enalapril in patients with essential hypertension. Cardiovasc Drugs Ther. 1996;10(3):313-9. Exclude: Followup < 12 wk. [pmid: 8877074].
Cha YJ, Pearson VE. Angioedema due to losartan. Ann Pharmacother. 1999;33(9):936-8. Exclude: Followup < 12 wk. [pmid: 10492494].
Chan P, Tomlinson B, Huang TY, et al. Double-blind comparison of losartan, lisinopril, and metolazone in elderly hypertensive patients with previous angiotensin-converting enzyme inhibitor-induced cough. J Clin Pharmacol. 1997;37(3):253-7. Exclude: Followup < 12 wk. [pmid: 9089428].
Chanudet X, De Champvallins M. Antihypertensive efficacy and tolerability of low-dose perindopril/indapamide combination compared with losartan in the treatment of essential hypertension. Int J Clin Pract. 2001;55(4):233-9. Exclude: Not ACEI vs. ARB. [pmid: 11406907].
Chapman AB, Torres VE, Perrone RD, et al. The HALT polycystic kidney disease trials: design and implementation. Clinical Journal of The American Society of Nephrology: CJASN. 2010;5(1):102-9. Exclude - ACE + drug X versus ARB + drug Y. [pmid: 20089507].
Chen JH, Cheng JJ, Chen CY, et al. Comparison of the efficacy and tolerability of telmisartan 40 mg vs. enalapril 10 mg in the treatment of mild-to-moderate hypertension: a multicentre, double-blind study in Taiwanese patients. Int J Clin Pract Suppl. 2004;(145):29-34. Exclude: Followup < 12 wk. [pmid: 15617456].
Chen K, Chiou CF, Plauschinat CA, et al. Patient satisfaction with antihypertensive therapy. J Hum Hypertens. 2005;19(10):793-9. Exclude: Followup < 12 wk. [pmid: 15951740].
Cheung R, Lewanczuk RZ, Rodger NW, et al. The effect of valsartan and captopril on lipid parameters in patients with type II diabetes mellitus and nephropathy. Int J Clin Pract. 1999;53(8):584-92. Exclude: No separate results for subgroup with hypertension. [pmid: 10692751].
Chiou KR, Chen CH, Ding PY, et al. Randomized, double-blind comparison of irbesartan and enalapril for treatment of mild to moderate hypertension. Chung Hua I Hsueh Tsa Chih. 2000;63(5):368-76. Exclude: Followup < 12 wk. [pmid: 10862446].
Chowta KN, Chowta MN, Bhat P, et al. An open comparative clinical trial to assess the efficacy and safety of losartan versus enalapril in mild to moderate hypertension. J Assoc Physicians India. 2002;50:1236-9. Exclude: Followup < 12 wk. [pmid: 12568205].
Ciulla MM, Paliotti R, Esposito A, et al. Effects of antihypertensive treatment on ultrasound measures of myocardial fibrosis in hypertensive patients with left ventricular hypertrophy: results of a randomized trial comparing the angiotensin receptor antagonist, candesartan and the angiotensin-converting enzyme inhibitor, enalapril. Journal of Hypertension. 2009;27(3):626-32. Full Text: Exclude - no outcomes of interest. [pmid: 19262230].
Cowan BR, Young AA, Anderson C, et al. Left Ventricular Mass and Volume With Telmisartan, Ramipril, or Combination in Patients With Previous Atherosclerotic Events or With Diabetes Mellitus (from the ONgoing Telmisartan Alone and in Combination With Ramipril Global Endpoint Trial [ONTARGET]). American Journal of Cardiology. 2009;104(11):1484-1489. Full Text: Exclude - HTN outcomes not reported separately. [pmid: 19932779].
Critchley JA, Gilchrist N, Ikeda L, et al. A randomized, double-masked comparison of the antihypertensive efficacy and safety of combination therapy with losartan and hydrochlorothiazide versus captopril and hydrochlorothiazide in elderly and younger patients. Curr Ther Res Clin Exp. 1996;57(5):392-407. Exclude: Could not obtain copy.
Cuocolo A, Storto G, Izzo R, et al. Effects of valsartan on left ventricular diastolic function in patients with mild or moderate essential hypertension: comparison with enalapril. J Hypertens. 1999;17(12 Pt 1):1759-66. Exclude: Followup < 12 wk. [pmid: 10658943].
de la Sierra A, Gil-Extremera B, Calvo C, et al. Comparison of the antihypertensive effects of the fixed dose combination enalapril 10 mg/nitrendipine 20 mg vs losartan 50 mg/hydrochlorothiazide 12.5 mg, assessed by 24-h ambulatory blood pressure monitoring, in essential hypertensive patients. J Hum Hypertens. 2004;18(3):215-22. Exclude: Followup < 12 wk. [pmid: 14973517].
Delles C, Jacobi J, John S, et al. Effects of enalapril and eprosartan on the renal vascular nitric oxide system in human essential hypertension. Kidney Int. 2002;61(4):1462-8. Exclude: Followup < 12 wk. [pmid: 11918753].
Delles C, Schneider MP, John S, et al. Angiotensin converting enzyme inhibition and angiotensin II AT1-receptor blockade reduce the levels of asymmetrical N(G), N(G)-dimethylarginine in human essential hypertension. Am J Hypertens. 2002;15(7 Pt 1):590-3. Exclude: Followup < 12 wk. [pmid: 12118904].
Derosa G, Ferrari I, Cicero AF. Irbesartan and hydrochlorothiazide association in the treatment of hypertension. Current Vascular Pharmacology. 2009;7(2):120-36. Full Text: Exclude - not a clinical trial. [pmid: 19355995].
Diamond JA, Gharavi A, Roychoudhury D, et al. Effect of long-term eprosartan versus enalapril antihypertensive therapy on left ventricular mass and coronary flow reserve in stage I-II hypertension. Eprosartan Study Group. Curr Med Res Opin. 1999;15(1):1-8. Exclude: Could not obtain copy. [pmid: 10216805].
Donmez G, Derici U, Erbas D, et al. The effects of losartan and enalapril therapies on the levels of nitric oxide, malondialdehyde, and glutathione in patients with essential hypertension. Jpn J Physiol. 2002;52(5):435-40. Exclude: Followup < 12 wk. [pmid: 12533248].
Donner KM, Hiltunen TP, Suonsyrja T, et al. CYP2C9 genotype modifies activity of the renin-angiotensin-aldosterone system in hypertensive men. Journal of Hypertension. 2009;27(10):2001-9. Exclude - reported drug not on our list. [pmid: 19593208].
Dowlatshahi D, Hill MD. Angiotensin receptor blockers and secondary stroke prevention: the MOSES study. Expert Review of Cardiovascular Therapy. 2009;7(5):459-64. Full Text: Exclude - not a clinical trial. [pmid: 19419253].
el-Agroudy AE, Hassan NA, Foda MA, et al. Effect of angiotensin II receptor blocker on plasma levels of TGF-beta 1 and interstitial fibrosis in hypertensive kidney transplant patients. Am J Nephrol. 2003;23(5):300-6. Exclude: Not essential hypertension. [pmid: 12904684].
Erdem Y, Usalan C, Haznedaroglu IC, et al. Effects of angiotensin converting enzyme and angiotensin II receptor inhibition on impaired fibrinolysis in systemic hypertension. Am J Hypertens. 1999;12(11 Pt 1):1071-6. Exclude: No outcomes of interest. [pmid: 10604482].
Erley CM, Bader B, Scheu M, et al. Renal hemodynamics in essential hypertensives treated with losartan. Clin Nephrol. 1. 1995;43:S8-11. Exclude: Followup < 12 wk. [pmid: 7781206].
Fagard R, Lijnen P, Pardaens K, et al. A randomised, placebo-controlled, double-blind, crossover study of losartan and enalapril in patients with essential hypertension. J Hum Hypertens. 2001;15(3):161-7. Exclude: Followup < 12 wk. [pmid: 11317199].
Falaschetti E, Chaudhury M, Mindell J, et al. Continued improvement in hypertension management in England: results from the Health Survey for England 2006. see comment. Hypertension. 2009;53(3):480-6. Full Text: Exclude - no outcomes of interest/no direct comparison. [pmid: 19204180].
Feldman RD, Zou GY, Vandervoort MK, et al. A simplified approach to the treatment of uncomplicated hypertension: a cluster randomized, controlled trial. see comment. Hypertension. 2009;53(4):646-53. Full Text: Exclude - no direct comparison. [pmid: 19237683].
Fogari R, Zoppi A, Carretta R, et al. Effect of indomethacin on the antihypertensive efficacy of valsartan and lisinopril: a multicentre study. J Hypertens. 2002;20(5):1007-14. Exclude: Followup < 12 wk. [pmid: 12011663].
Fogari R, Zoppi A, Corradi L, et al. Comparative effects of lisinopril and losartan on insulin sensitivity in the treatment of non diabetic hypertensive patients. Br J Clin Pharmacol. 1998;46(5):467-71. Exclude: Followup < 12 wk. [pmid: 9833600].
Fogari R, Zoppi A, Lazzari P, et al. ACE inhibition but not angiotensin II antagonism reduces plasma fibrinogen and insulin resistance in overweight hypertensive patients. J Cardiovasc Pharmacol. 1998;32(4):616-20. Exclude: Followup < 12 wk. [pmid: 9781930].
Fox JC, Leight K, Sutradhar SC, et al. The JNC 7 approach compared to conventional treatment in diabetic patients with hypertension: a double-blind trial of initial monotherapy vs. combination therapy. J Clin Hypertens (Greenwich). 2004;6(8):437-42. quiz 443-4. Exclude: Followup < 12 wk. [pmid: 15308882].
Franchi F, Lazzeri C, Foschi M, et al. Cardiac autonomic tone during trandolapril-irbesartan low-dose combined therapy in hypertension: a pilot project. J Hum Hypertens. 2002;16(8):597-604. Exclude: Followup < 12 wk. [pmid: 12149667].
Gainer JV, Morrow JD, Loveland A, et al. Effect of bradykinin-receptor blockade on the response to angiotensin-converting-enzyme inhibitor in normotensive and hypertensive subjects. N Engl J Med. 1998;336(18):1285-92. Exclude: Followup < 12 wk. [pmid: 9791144].
Gansevoort RT, de Zeeuw D, de Jong PE. Is the antiproteinuric effect of ACE inhibition mediated by interference in the renin-angiotensin system?. Kidney Int. 1994;45(3):861-7. Exclude: Followup < 12 wk. [pmid: 8196289].
Geiger H, Barranco E, Gorostidi M, et al. Combination therapy with various combinations of aliskiren, valsartan, and hydrochlorothiazide in hypertensive patients not adequately responsive to hydrochlorothiazide alone. Journal of Clinical Hypertension. 2009;11(6):324-32. Full Text: Exclude - Duration < 12 wks. [pmid: 19527323].
Gleason PP. Assessing step-therapy programs:a step in the right direction. [see comment][comment]. Journal of Managed Care Pharmacy. 2007;13(3):273-5. Full Text: Exclude - not a clinical trial. [pmid: 17407393].
Goldberg MR, Bradstreet TE, McWilliams EJ, et al. Biochemical effects of losartan, a nonpeptide angiotensin II receptor antagonist, on the renin-angiotensin-aldosterone system in hypertensive patients. Hypertension. 1995;25(1):37-46. Exclude: Followup < 12 wk. [pmid: 7843751].
Gosse P, Neutel JM, Schumacher H, et al. The effect of telmisartan and ramipril on early morning blood pressure surge: a pooled analysis of two randomized clinical trials. Blood Pressure Monitoring. 2007;12(3):141-7. Full Text: Exclude - duplicate publication. [pmid: 17496463].
Gradman AH, Arcuri KE, Goldberg AI, et al. A randomized, placebo-controlled, double-blind, parallel study of various doses of losartan potassium compared with enalapril maleate in patients with essential hypertension. Hypertension. 1995;25(6):1345-50. Exclude: Followup < 12 wk. [pmid: 7768585].
Gradman AH, Schmieder RE, Lins RL, et al. Aliskiren, a novel orally effective renin inhibitor, provides dose-dependent antihypertensive efficacy and placebo-like tolerability in hypertensive patients. Circulation. 2005;111(8):1012-8. Full Text: Exclude - not a clinical trial. [pmid: 15723979].
Grandi AM, Solbiati F, Laurita E, et al. Effects of dual blockade of Renin-Angiotensin system on concentric left ventricular hypertrophy in essential hypertension: a randomized, controlled pilot study. American Journal of Hypertension. 2008;21(2):231-7. Full Text: Exclude - compares ACEIs/drugX vs ARBs/drugY. [pmid: 18174880].
Guasti L, Petrozzino MR, Mainardi LT, et al. Autonomic function and baroreflex sensitivity during angiotensin-converting enzyme inhibition or angiotensin II AT-1 receptor blockade in essential hypertensive patients. Acta Cardiol. 2001;56(5):289-95. Exclude: Followup < 12 wk. [pmid: 11712824].
Guasti L, Zanotta D, Diolisi A, et al. Changes in pain perception during treatment with angiotensin converting enzyme-inhibitors and angiotensin II type 1 receptor blockade. J Hypertens. 2002;20(3):485-91. Exclude: Followup < 12 wk. [pmid: 11875316].
Han SW, Won YW, Yi JH, et al. No impact of hyperkalaemia with renin-angiotensin system blockades in maintenance haemodialysis patients. Nephrology Dialysis Transplantation. 2007;22(4):1150-1155. Full Text: Exclude - duration < 12 weeks.
Hannedouche T, Chanard J, Baumelou B, et al. Evaluation of the safety and efficacy of telmisartan and enalapril, with the potential addition of frusemide, in moderate-renal failure patients with mild-to-moderate hypertension. J Renin Angiotensin Aldosterone Syst. 2001;2(4):246-54. Exclude: Followup < 12 wk. [pmid: 11881131].
Hartog JWL, Van De Wal RM, Schalkwijk CG, et al. Advanced glycation end-products, anti-hypertensive treatment and diastolic function in patients with hypertension and diastolic dysfunction. European Journal of Heart Failure. 2010;12(4):397-403. Exclude - ACEI + drug X vs ARB + drug Y. [pmid: 20154337].
Hasler C, Nussberger J, Maillard M, et al. Sustained 24-hour blockade of the renin-angiotensin system: a high dose of a long-acting blocker is as effective as a lower dose combined with an angiotensin-converting enzyme inhibitor. Clin Pharmacol Ther. 2005;78(5):501-7. Exclude: Followup < 12 wk. [pmid: 16321616].
Haymore BR, Yoon J, Mikita CP, et al. Risk of angioedema with angiotensin receptor blockers in patients with prior angioedema associated with angiotensin-converting enzyme inhibitors: a meta-analysis. Annals of Allergy, Asthma, & Immunology. 2008;101(5):495-9. Exclude - meta-analysis for background.
Heckbert SR, Wiggins KL, Glazer NL, et al. Antihypertensive treatment with ACE inhibitors or beta-blockers and risk of incident atrial fibrillation in a general hypertensive population. American Journal of Hypertension. 2009;22(5):538-44. Full Text: Exclude - no direct comparison. [pmid: 19265792].
Hedner T, Oparil S, Rasmussen K, et al. A comparison of the angiotensin II antagonists valsartan and losartan in the treatment of essential hypertension. Am J Hypertens. 1999;12(4 Pt 1):414-7. Exclude: Followup < 12 wk. [pmid: 10232502].
Heran BS, Wong MMY, Heran IK, et al. Blood pressure lowering efficacy of angiotensin receptor blockers for primary hypertension. Cochrane Database of Systematic Reviews. 2009;(4). Exclude - systematic review for background.
Hillebrand U, Suwelack BM, Loley K, et al. Blood pressure, antihypertensive treatment, and graft survival in kidney transplant patients. Transplant International. 2009;22(11):1073-80. Exclude - no outcomes of interest. [pmid: 19624495].
Himmelmann A, Keinanen-Kiukaanniemi S, Wester A, et al. The effect duration of candesartan cilexetil once daily, in comparison with enalapril once daily, in patients with mild to moderate hypertension. Blood Press. 2001;10(1):43-51. Exclude: Followup < 12 wk. [pmid: 11332334].
Hirschl MM, Bur A, Woisetschlaeger C, et al. Effects of candesartan and lisinopril on the fibrinolytic system in hypertensive patients. Journal of Clinical Hypertension. 2007;9(6):430-5. Full Text: Exclude - duration < 12 wks. [pmid: 17541328].
Holwerda NJ, Fogari R, Angeli P, et al. Valsartan, a new angiotensin II antagonist for the treatment of essential hypertension: efficacy and safety compared with placebo and enalapril. J Hypertens. 1996;14(9):1147-51. Exclude: Followup < 12 wk. [pmid: 8986917].
Hong L, Maoyin C, Ping C, et al. Comparison of losartan and benazepril for the treatment of mild and moderate essential hypertension. Acta Academiae Medicinae Hubei. 2000;21(3):211-3. Exclude: Followup < 12 wk.
Hou FF, Xie D, Zhang X, et al. Renoprotection of Optimal Antiproteinuric Doses (ROAD) Study: a randomized controlled study of benazepril and losartan in chronic renal insufficiency. see comment. Journal of the American Society of Nephrology. 2007;18(6):1889-98. Full Text: Exclude - results inadequately reported. [pmid: 17494885].
Igarashi M, Hirata A, Kadomoto Y, et al. Dual blockade of angiotensin II with enalapril and losartan reduces proteinuria in hypertensive patients with type 2 diabetes. Endocrine Journal. 2006;53(4):493-501. Full Text: Exclude - no direct comparison. [pmid: 16829707].
Iimura O, Shimamoto K, Matsuda K, et al. Effects of angiotensin receptor antagonist and angiotensin converting enzyme inhibitor on insulin sensitivity in fructose-fed hypertensive rats and essential hypertensives. Am J Hypertens. 1995;8(4 Pt 1):353-7. Exclude: Followup < 12 wk. [pmid: 7619347].
Ito A, Egashira K, Narishige T, et al. Renin-angiotensin system is involved in the mechanism of increased serum asymmetric dimethylarginine in essential hypertension. Jpn Circ J. 2001;65(9):775-8. Exclude: Followup < 12 wk. [pmid: 11548874].
Jilma B, Li-Saw-Hee FL, Wagner OF, et al. Effects of enalapril and losartan on circulating adhesion molecules and monocyte chemotactic protein-1. Clin Sci (Colch). 2002;103(2):131-6. Exclude: Followup < 12 wk. [pmid: 12149103].
Jordan J, Engeli S, Boye SW, et al. Direct Renin inhibition with aliskiren in obese patients with arterial hypertension. Hypertension. 2007;49(5):1047-55. Full Text: Exclude - duration < 12 weeks. [pmid: 17353513].
Joshi SR, Yeolekar ME, Tripathi KK, et al. Evaluation of efficacy and tolerability of Losartan and Ramipril combination in the management of hypertensive patients with associated diabetes mellitus in India (LORD Trial). J Assoc Physicians India. 2004;52:189-95. Exclude: Not ACEI vs. ARB. [pmid: 15636307].
Kaplan NM. Recent clinical trials: the good, the bad, and the misleading. see comment. Hypertension. 2008;52(4):608-9. Full Text: Exclude - not a clinical trial. [pmid: 18695142].
Kaplan NM. TROPHY: a trial that may change clinical practice. Current Hypertension Reports. 2006;8(5):359-60. Full Text: Exclude - not a clinical trial. [pmid: 16965719].
Karas M, Lacourciere Y, LeBlanc AR, et al. Effect of the renin-angiotensin system or calcium channel blockade on the circadian variation of heart rate variability, blood pressure and circulating catecholamines in hypertensive patients. J Hypertens. 2005;23(6):1251-60. Exclude: Followup < 12 wk. [pmid: 15894902].
Karotsis AK, Symeonidis A, Mastorantonakis SE, et al. Additional antihypertensive effect of drugs in hypertensive subjects uncontrolled on diltiazem monotherapy: a randomized controlled trial using office and home blood pressure monitoring. Clinical & Experimental Hypertension (New York). 2006;28(7):655-62. Full Text: Exclude - Duration < 12 wks.
Kashiwagi A. Reduction of microalbuminuria in patients with type 2 diabetes. The Shiga Microalbuminuria Reduction Trial (SMART). Diabetes Care. 2007;30(6):1581-1583. Full Text: Exclude - study drug not on our list. [pmid: 17363751].
Kim W, Lee S, Kang SK, et al. Effects of angiotensin converting enzyme inhibitor and angiotensin II receptor antagonist therapy in hypertensive renal transplant recipients. Transplant Proc. 2002;34(8):3223-4. Exclude: Followup < 12 wk. [pmid: 12493427].
Kiski D, Stepper W, Brand E, et al. Impact of renin-angiotensin-aldosterone blockade by angiotensin-converting enzyme inhibitors or AT-1 blockers on frequency of contrast medium-induced nephropathy: a post-hoc analysis from the Dialysis-versus-Diuresis (DVD) trial. Nephrology Dialysis Transplantation. 2010;25(3):759-64. Exclude - results don't report HTN separately.
Klein IH, Ligtenberg G, Oey PL, et al. Enalapril and losartan reduce sympathetic hyperactivity in patients with chronic renal failure. J Am Soc Nephrol. 2003;14(2):425-30. Exclude: Followup < 12 wk. [pmid: 12538743].
Knauf H, Bailey MA, Hasenfuss G, et al. The influence of cardiovascular and antiinflammatory drugs on thiazide-induced hemodynamic and saluretic effects. European Journal of Clinical Pharmacology. 2006;62(11):885-92. Full Text: Exclude - no outcomes of interest/no pt has essential HTN. [pmid: 16964522].
Knudsen ST, Andersen NH, Poulsen SH, et al. Pulse pressure lowering effect of dual blockade with candesartan and lisinopril vs. high-dose ACE inhibition in hypertensive type 2 diabetic subjects: a CALM II study post-hoc analysis. see comment. American Journal of Hypertension. 2008;21(2):172-6. Full Text: Exclude - no direct comparison. [pmid: 18188164].
Koh KK, Quon MJ, Lee Y, et al. Additive beneficial cardiovascular and metabolic effects of combination therapy with ramipril and candesartan in hypertensive patients. European Heart Journal. 2007;28(12):1440-7. Full Text: Exclude - duration < 12 weeks. [pmid: 17483542].
Koh KK, Quon MJ, Han SH, et al. Distinct vascular and metabolic effects of different classes of anti-hypertensive drugs. International Journal of Cardiology. 2010;140(1):73-81. Exclude - duration < 12 weeks (8). [pmid: 19059660].
Kraiczi H, Hedner J, Peker Y, et al. Comparison of atenolol, amlodipine, enalapril, hydrochlorothiazide, and losartan for antihypertensive treatment in patients with obstructive sleep apnea. Am J Respir Crit Care Med. 2000;161(5):1423-8. Exclude: Followup < 12 wk. [pmid: 10806134].
Lacourciere Y, Brunner H, Irwin R, et al. Effects of modulators of the renin-angiotensin-aldosterone system on cough. Losartan Cough Study Group. J Hypertens. 1994;12(12):1387-93. Exclude: Followup < 12 wk. [pmid: 7706699].
Lacourciere Y, Lefebvre J. Modulation of the renin-angiotensin-aldosterone system and cough. Can J Cardiol. F. 1995;11:33F-9F. Exclude: Followup < 12 wk.
Lacourciere Y. A multicenter, randomized, double-blind study of the antihypertensive efficacy and tolerability of irbesartan in patients aged > or = 65 years with mild to moderate hypertension. Clin Ther. 2000;22(10):1213-24. Exclude: Followup < 12 wk. [pmid: 11110232].
Lacourciere Y. The incidence of cough: a comparison of lisinopril, placebo and telmisartan, a novel angiotensin II antagonist. Telmisartan Cough Study Group. Int J Clin Pract. 1999;53(2):99-103. Exclude: Followup < 12 wk. [pmid: 10344043].
Laragh JH, Case DB, Wallace JM, et al. Blockade of renin or angiotensin for understanding human hypertension: a comparison of propranolol, saralasin and converting enzyme blockade. Federation Proceedings. 1977;36(5):1781-7. Full Text: Exclude - study drug not on our included list. [pmid: 191300].
Lee CM, Lee YT, Lang MG, et al. A comparison of valsartan and captopril in Taiwanese patients with essential hypertension. Adv Ther. 1999;16(1):39-48. Exclude: Followup < 12 wk.
Lee YJ, Chiang YF, Tsai JC. Severe nonproductive cough and cough-induced stress urinary incontinence in diabetic postmenopausal women treated with ACE inhibitor. Diabetes Care. 2000;23(3):427-8. Exclude: Followup < 12 wk. [pmid: 10868884].
Leu HB, Charng MJ, Ding PY. A double blind randomized trial to compare the effects of eprosartan and enalapril on blood pressure, platelets, and endothelium function in patients with essential hypertension. Jpn Heart J. 2004;45(4):623-35. Exclude: Followup < 12 wk. [pmid: 15353873].
Lewandowski J, Abramczyk P, Dobosiewicz A, et al. The effect of enalapril and telmisartan on clinical and biochemical indices of sympathetic activity in hypertensive patients. Clinical & Experimental Hypertension (New York). 2008;30(5):423-32. Full Text: Exclude - duration < 12 weeks.
Li NC, Lee A, Whitmer RA, et al. Use of angiotensin receptor blockers and risk of dementia in a predominantly male population: Prospective cohort analysis. BMJ. 2010;340(7738):141. Exclude - no pt has essential HTN.
Liau BY, Chiu CC, Yeh SJ. Assessment of dynamic cerebral autoregulation using spectral and cross-correlation analyses of different antihypertensive drug treatments. Journal of Medical and Biological Engineering. 2010;30(3):169-176.
Li-Saw-Hee FL, Beevers DG, Lip GY. Effect of antihypertensive therapy using enalapril or losartan on haemostatic markers in essential hypertension: a pilot prospective randomised double-blind parallel group trial. Int J Cardiol. 2001;78(3):241-6. Exclude: Followup < 12 wk. [pmid: 11376827].
Mahmud A, Feely J. Favourable effects on arterial wave reflection and pulse pressure amplification of adding angiotensin II receptor blockade in resistant hypertension. J Hum Hypertens. 2000;14(9):541-6. Exclude: Followup < 12 wk. [pmid: 10980584].
Mahmud A, Feely J. Reduction in arterial stiffness with angiotensin II antagonist is comparable with and additive to ACE inhibition. Am J Hypertens. 2002;15(4 Pt 1):321-5. Exclude: Followup < 12 wk. [pmid: 11991217].
Mallion JM, Boutelant S, Chabaux P, et al. Valsartan, a new angiotensin II antagonist blood pressure reduction in essential hypertension compared with an angiotensin converting enzyme inhibitor, enalapril. Blood Press Monit. 1997;2(3-4):179-84. Exclude: Could not obtain copy. [pmid: 10234113].
Masri G, Bledsoe K, Palacio C. Characteristics of patients prescribed angiotensin-converting enzyme inhibitors, angiotensin receptor blockers, or the combination at an urban medical center. Medgenmed [Computer File]. Medscape General Medicine. 2007;9(4):40. Full Text: Exclude - duration < 12 weeks. [pmid: 18311390].
Matchar DB, McCrory DC, Orlando LA, et al. Comparative Effectiveneness of Angiotensin-Converting Enzyme Inhibitors (ACEIs) and Angiotensin II Receptor Antagonists (ARBs) for Treating Essential Hypertension, Comparative Effectiveness Review No. 10. (Prepared by Duke Evidence-based Practice Center under Contract No. 290-02-0025.). Rockville, MD. Agency for Healthcare Research and Quality. November. 2007. Available at: www.effectivehealthcare.ahrq.gov/reports/final.cfm. March 30, 2010. 2007. Exclude - original CER from AHRQ.
Matsumoto T, Minai K, Horie H, et al. Angiotensin-converting enzyme inhibition but not angiotensin II type 1 receptor antagonism augments coronary release of tissue plasminogen activator in hypertensive patients. J Am Coll Cardiol. 2003;41(8):1373-9. Exclude: Followup < 12 wk. [pmid: 12706934].
Mehdi UF, Adams-Huet B, Raskin P, et al. Addition of angiotensin receptor blockade or mineralocorticoid antagonism to maximal angiotensin-converting enzyme inhibition in diabetic nephropathy. Journal of the American Society of Nephrology. 2009;20(12):2641-50. Exclude - doesn't compare ACEIs vs ARBs. [pmid: 19926893].
Miller DR, Oliveria SA, Berlowitz DR, et al. Angioedema incidence in US veterans initiating angiotensin-converting enzyme inhibitors. Hypertension. 2008;51(6):1624-30. Exclude - no comparator. [pmid: 18413488].
Mimura T, Takenaka T, Kanno Y, et al. Vascular compliance is secured under angiotensin inhibition in non-diabetic chronic kidney diseases. Journal of Human Hypertension. 2008;22(1):38-47. Full Text: Exclude - no pt has essential HTN. [pmid: 17653243].
Mohsen Ibrahim M, Igho-Pemu P, Singh D, et al. Angiotension receptor blockers may be similarly effective to other antihypertensive drugs for primary prevention in the short term. Evidence-based Cardiovascular Medicine. 2006;10(2):89-93. Full Text: Exclude - not a clinical trial. [pmid: 16753502].
Moore N, Dicker P, O'Brien JK, et al. Renin gene polymorphisms and haplotypes, blood pressure, and responses to renin-angiotensin system inhibition. Hypertension. 2007;50(2):340-7. Full Text: Exclude - duration < 12 weeks. [pmid: 17562974].
Morgan T, Anderson A, Bertram D, et al. Effect of candesartan and lisinopril alone and in combination on blood pressure and microalbuminuria. J Renin Angiotensin Aldosterone Syst. 2004;5(2):64-71. Exclude: Followup < 12 wk. [pmid: 15295717].
Morgan T, Anderson A. Low-dose combination therapy with perindopril and indapamide compared with irbesartan. Clinical Drug Investigation. 2002;22(8):553-60. Exclude: Not ACEI vs. ARB.
Morimoto S, Maki K, Aota Y, et al. Beneficial effects of combination therapy with angiotensin II receptor blocker and angiotensin-converting enzyme inhibitor on vascular endothelial function. Hypertension Research - Clinical & Experimental. 2008;31(8):1603-10. Full Text: Exclude - no direct comparison.
Mourad JJ, Waeber B, Zannad F, et al. Comparison of different therapeutic strategies in hypertension: a low-dose combination of perindopril/indapamide versus a sequential monotherapy or a stepped-care approach. J Hypertens. 2004;22(12):2379-86. Exclude: Not ACEI vs. ARB. [pmid: 15614033].
Mugellini A, Preti P, Zoppi A, et al. Effect of delapril-manidipine combination vs irbesartan-hydrochlorothiazide combination on fibrinolytic function in hypertensive patients with type II diabetes mellitus. J Hum Hypertens. 2004;18(10):687-91. Exclude: Not ACEI vs. ARB. [pmid: 15071488].
Mulatero P, Rabbia F, Milan A, et al. Drug effects on aldosterone/plasma renin activity ratio in primary aldosteronism. Hypertension. 2002;40(6):897-902. Exclude: Followup < 12 wk. [pmid: 12468576].
Nagano M, Higaki J, Mikami H, et al. Role of the renin-angiotensin system in hypertension in the elderly. Blood Press Suppl. 1994;5:130-3. Exclude: Followup < 12 wk. [pmid: 7889195].
Nakamoto H, Kanno Y, Okada H, et al. Erythropoietin resistance in patients on continuous ambulatory peritoneal dialysis. Adv Perit Dial. 2004;20:111-6. Exclude: Not essential hypertension. [pmid: 15384808].
Nalbantgil S, Yilmaz H, Gurun C, et al. Effects of valsartan and enalapril on regression of left ventricular hypertrophy in patients with mild to moderate hypertension: A randomized, double-blind study. Curr Ther Res Clin Exp. 2000;61(6):331-8. Exclude: Could not obtain copy.
Narkiewicz K. Comparison of home and office blood pressure in hypertensive patients treated with zofenopril or losartan. Blood Pressure Supplement. 2007;2:7-12. Full Text: Exclude - study drug not on our included list. [pmid: 18046973].
Nawarskas JJ, Townsend RR, Cirigliano MD, et al. Effect of aspirin on blood pressure in hypertensive patients taking enalapril or losartan. Am J Hypertens. 1999;12(8 Pt 1):784-9. Exclude: N < 20. [pmid: 10480471].
Neki NS, Arora P. A comparative evaluation of therapeutic effects of once a day dose of losartan potassium versus enalapril maleate in mild to moderate essential hypertension. J Indian Med Assoc. 2001;99(11):640-1. Exclude: Followup < 12 wk. [pmid: 12022207].
Neumann J, Ligtenberg G, Klein IH, et al. Sympathetic hyperactivity in hypertensive chronic kidney disease patients is reduced during standard treatment. see comment. Hypertension. 2007;49(3):506-10. Full Text: Exclude - duration < 12 weeks. [pmid: 17224471].
Neutel JM, Schumacher H, Gosse P, et al. Magnitude of the early morning blood pressure surge in untreated hypertensive patients: A pooled analysis. International Journal of Clinical Practice. 2008;62(11):1654-1663. Full Text: Exclude - not a clinical trial. [pmid: 18795972].
Neutel JM, Smith DH, Reilly PA. The efficacy and safety of telmisartan compared to enalapril in patients with severe hypertension. Int J Clin Pract. 1999;53(3):175-8. Exclude: Followup < 12 wk. [pmid: 10665127].
Nussberger J, Gradman AH, Schmieder RE, et al. Plasma renin and the antihypertensive effect of the orally active renin inhibitor aliskiren in clinical hypertension. see comment. International Journal of Clinical Practice. 2007;61(9):1461-8. Full Text: Exclude - duration < 12 weeks. [pmid: 17590217].
O'Brien E, Barton J, Nussberger J, et al. Aliskiren reduces blood pressure and suppresses plasma renin activity in combination with a thiazide diuretic, an angiotensin-converting enzyme inhibitor, or an angiotensin receptor blocker. see comment. Hypertension. 2007;49(2):276-84. Full Text: Exclude - duration < 12 weeks. [pmid: 17159081].
Ogawa S, Mori T, Nako K, et al. Angiotensin II type 1 receptor blockers reduce urinary oxidative stress markers in hypertensive diabetic nephropathy. Hypertension. 2006;47(4):699-705. Full Text: Exclude - study drug not on our included list. [pmid: 16505207].
Ogawa S, Takeuchi K, Mori T, et al. Effects of monotherapy of temocapril or candesartan with dose increments or combination therapy with both drugs on the suppression of diabetic nephropathy. Hypertension Research - Clinical & Experimental. 2007;30(4):325-34. Full Text: Exclude - study drug not on our included list.
Okuguchi T, Osanai T, Fujiwara N, et al. Effect of losartan on nocturnal blood pressure in patients with stroke: comparison with angiotensin converting enzyme inhibitor. Am J Hypertens. 2002;15(11):998-1002. Exclude: Followup < 12 wk. [pmid: 12441222].
Ong HT, Rozina G. Selecting antihypertensive medication in patients with essential hypertension in Malaysia. Medical Journal of Malaysia. 2009;64(1):3-11. Full Text: Exclude - not a clinical study. [pmid: 19852313].
Oparil S, Yarows SA, Patel S, et al. Efficacy and safety of combined use of aliskiren and valsartan in patients with hypertension: a randomised, double-blind trial. [see comment][erratum appears in Lancet. 2007 Nov 3;370(9598):1542]. Lancet. 2007;370(9583):221-9. Full Text: Exclude - duration < 12 weeks. [pmid: 17658393].
Oparil S. Eprosartan versus enalapril in hypertensive patients with angiotensin- converting enzyme inhibitor-induced cough. Curr Ther Res Clin Exp. 1999;60(1):1-4. Exclude: Followup < 12 wk.
Palma-Gamiz JL, Pego M, Marquez E, et al. A multicentre, 12-week study of imidapril and candesartan cilexetil in patients with mild to moderate hypertension using ambulatory blood pressure monitoring. Clinical Drug Investigation. 2007;27(6):407-17. Full Text: Exclude - study drug not on our included list. [pmid: 17506591].
Palmas W, Ma S, Psaty B, et al. Antihypertensive medications and C-reactive protein in the multi-ethnic study of atherosclerosis. American Journal of Hypertension. 2007;20(3):233-41. Full Text: Exclude - no direct comparison. [pmid: 17324732].
Papademetriou V, Narayan P, Kokkinos P. Angiotensin-converting enzyme inhibitors and angiotensin receptor blockers in African-American patients with hypertension. J Clin Hypertens (Greenwich). 2004;6(6):310-4. Exclude: Followup < 12 wk. [pmid: 15187493].
Parving HH, Persson F, Lewis JB, et al. Aliskiren combined with losartan in type 2 diabetes and nephropathy. [see comment][reprint in Ugeskr Laeger. 2009 Mar 9;171(11):881-4; PMID:19291865]. New England Journal of Medicine. 2008;358(23):2433-46. Full Text: Exclude - no direct comparison. [pmid: 18525041].
Paster RZ, Snavely DB, Sweet AR, et al. Use of losartan in the treatment of hypertensive patients with a history of cough induced by angiotensin-converting enzyme inhibitors. Clin Ther. 1998;20(5):978-89. Exclude: Followup < 12 wk. [pmid: 9829449].
Pechere-Bertschi A, Nussberger J, Decosterd L, et al. Renal response to the angiotensin II receptor subtype 1 antagonist irbesartan versus enalapril in hypertensive patients. J Hypertens. 1998;16(3):385-93. Exclude: Followup < 12 wk. [pmid: 9557932].
Persson F, Rossing P, Reinhard H, et al. Renal effects of aliskiren compared with and in combination with irbesartan in patients with type 2 diabetes, hypertension, and albuminuria. Diabetes Care. 2009;32(10):1873-1879. Full Text: Exclude - duration < 12 weeks. [pmid: 19587362].
Phakdeekitcharoen B, Leelasa-nguan P. Effects of an ACE inhibitor or angiotensin receptor blocker on potassium in CAPD patients. Am J Kidney Dis. 2004;44(4):738-46. Exclude: Followup < 12 wk. [pmid: 15384026].
Pierson CA, Epstein BJ, Roberts ME. The importance of managing cardiovascular risk in the treatment of hypertension: the role of ACE inhibitors and ARBs. Journal of the American Academy of Nurse Practitioners. 2008;20(11):529-38. Full Text: Exclude - not a clinical trial. [pmid: 19128336].
Poirier L, de Champlain J, Larochelle P, et al. A comparison of the efficacy and duration of action of telmisartan, amlodipine and ramipril in patients with confirmed ambulatory hypertension. Blood Press Monit. 2004;9(5):231-6. Exclude: Followup < 12 wk. [pmid: 15472494].
Pool JL, Schmieder RE, Azizi M, et al. Aliskiren, an orally effective renin inhibitor, provides antihypertensive efficacy alone and in combination with valsartan. American Journal of Hypertension. 2007;20(1):11-20. Full Text: Exclude - duration < 12 weeks. [pmid: 17198906].
Prabowo P, Arwanto A, Soemantri D, et al. A comparison of valsartan and captopril in patients with essential hypertension in Indonesia. Int J Clin Pract. 1999;53(4):268-72. Exclude: Followup < 12 wk. [pmid: 10563070].
Preston RA, Baltodano NM, Alonso AB, et al. Comparative effects on dynamic renal potassium excretion of ACE inhibition versus angiotensin receptor blockade in hypertensive patients with type II diabetes mellitus. J Clin Pharmacol. 2002;42(7):754-61. Exclude: Followup < 12 wk. [pmid: 12092742].
Prikryl P, Cornelissen G, Neubauer J, et al. Chronobiologically explored effects of telmisartan. Clin Exper Hypertens. 2005;27(2-3):119-28. Exclude: Followup < 12 wk. [pmid: 15835374].
Ragot S, Genes N, Vaur L, et al. Comparison of three blood pressure measurement methods for the evaluation of two antihypertensive drugs: feasibility, agreement, and reproducibility of blood pressure response. Am J Hypertens. 2000;13(6 Pt 1):632-9. Exclude: Followup < 12 wk. [pmid: 10912746].
Rake EC, Breeze E, Fletcher AE. Quality of life and cough on antihypertensive treatment: a randomised trial of eprosartan, enalapril and placebo. J Hum Hypertens. 2001;15(12):863-7. Exclude: Followup < 12 wk. [pmid: 11773989].
Ramsay LE, Kirwan BA, for the Telmisartan Study Group (THESI). A comparison of cough in hypertensive patients receiving telmisartan, enalapril, or hydrochlorothiazide. J Hypertens. 2. 1998;16:S241. (Abstract P31.053). Exclude: Followup < 12 wk.
Ramsay LE, Yeo WW. ACE inhibitors, angiotensin II antagonists and cough. The Losartan Cough Study Group. J Hum Hypertens. 5. 1995;9:S51-4. Exclude: Followup < 12 wk. [pmid: 8583482].
Remkova A, Kratochvil'ova H, Durina J. Impact of the therapy by renin-angiotensin system targeting antihypertensive agents perindopril versus telmisartan on prothrombotic state in essential hypertension. Journal of Human Hypertension. 2008;22(5):338-345. Full Text: Exclude - duration < 12 weeks. [pmid: 18305548].
Riche DM, Minor DS, Holdiness AS, et al. An issue of dependence: implications from the Aliskiren in the Evaluation of Proteinuria in Diabetes (AVOID) trial. Journal of Clinical Hypertension. 2009;11(2):89-93. Full Text: Exclude - not a clinical trial. [pmid: 19222674].
Rippin J, Bain SC, Barnett AH, et al. Rationale and design of diabetics exposed to telmisartan and enalapril (DETAIL) study. J Diabetes Complications. 2002;16(3):195-200. Exclude: Trial methods & design (no published results as of 8 Dec 2006). [pmid: 12015188].
Ritt M, Ott C, Raff U, et al. Renal vascular endothelial function in hypertensive patients with type 2 diabetes mellitus. American Journal of Kidney Diseases. 2009;53(2):281-9. Full Text: Exclude - no direct comparison. [pmid: 19100670].
Rizzoni D, Porteri E, De Ciuceis C, et al. Effect of treatment with candesartan or enalapril on subcutaneous small artery structure in hypertensive patients with noninsulin-dependent diabetes mellitus. Hypertension. 2005;45(4):659-65. Exclude: N < 20. [pmid: 15723969].
Rosa EM, Viecceli C Jr. Interesting findings in the VALERIA trial. comment. Journal of Hypertension. 2009;27(4):902. author reply 902-3. Full Text: Exclude - not a clinical trial. [pmid: 19300116].
Saijonmaa O, Fyhrquist F. Can aliskiren reduce the incidence of cough caused by ramipril?. Journal of the Renin-Angiotensin-Aldosterone System. 2008;9(3):176. Exclude - not a clinical study. [pmid: 18957388].
Sarafidis PA, Stafylas PC, Kanaki AI, et al. Effects of renin-angiotensin system blockers on renal outcomes and all-cause mortality in patients with diabetic nephropathy: An updated meta-analysis. American Journal of Hypertension. 2008;21(8):922-929. Full Text: Exclude - not a clinical trial. [pmid: 18535536].
Saudan P, Halabi G, Perneger T, et al. ACE inhibitors or angiotensin II receptor blockers in dialysed patients and erythropoietin resistance. Journal of Nephrology. 2006;19(1):91-6. Full Text: Exclude - no outcomes of interest. [pmid: 16523432].
Sawada T, Takahashi T, Yamada H, et al. Rationale and design of the KYOTO HEART study: Effects of valsartan on morbidity and mortality in uncontrolled hypertensive patients with high risk of cardiovascular events. Journal of Human Hypertension. 2009;23(3):188-195. Full Text: Exclude - not a clinical trial. [pmid: 18800142].
Schaer BA, Schneider C, Jick SS, et al. Risk for incident atrial fibrillation in patients who receive antihypertensive drugs: a nested case-control study. Summary for patients in Ann Intern Med. 2010 Jan 19;152(2):I-16; PMID:20083810. Annals of Internal Medicine. 2010;152(2):78-84. Exclude - HTN data not reported separately. [pmid: 20083826].
Schmidt A, Gruber U, Bohmig G, et al. The effect of ACE inhibitor and angiotensin II receptor antagonist therapy on serum uric acid levels and potassium homeostasis in hypertensive renal transplant recipients treated with CsA. Nephrol Dial Transplant. 2001;16(5):1034-7. Exclude: Followup < 12 wk. [pmid: 11328912].
Schmieder RE, Delles C, Mimran A, et al. Impact of telmisartan versus ramipril on renal endothelial function in patients with hypertension and type 2 diabetes. erratum appears in Diabetes Care. 2007 Sep;30(9):2421. Diabetes Care. 2007;30(6):1351-6. Full Text: Exclude - duration < 12 weeks. [pmid: 17337492].
Scholze J, Stapff M. Start of therapy with the angiotensin II antagonist losartan after immediate switch from pretreatment with an ACE inhibitor. Br J Clin Pharmacol. 1998;46(2):169-72. Exclude: Followup < 12 wk. [pmid: 9723827].
Schulz E, Bech J, Pedersen EB, et al. Tolerability and antihypertensive efficacy of losartan vs captopril in patients with mild to moderate hypertension and impaired renal function. A randomised, double-blind, parallel study. Clinical Drug Investigation. 2000;19(3):183-94. Exclude: Not essential hypertension.
Schulz E, Bech JN, Pedersen EB, et al. A randomized, double-blind, parallel study on the safety and antihypertensive efficacy of losartan compared to captopril in patients with mild to moderate hypertension and impaired renal function. Nephrol Dial Transplant. 4. 1999;14:27-8. Exclude: Not essential hypertension. [pmid: 10463203].
Sega R. Efficacy and safety of eprosartan in severe hypertension. Eprosartan Multinational Study Group. Blood Press. 1999;8(2):114-21. Exclude: Followup < 12 wk. [pmid: 10451039].
Serebruany VL, Atar D, Hanley DF. Telmisartan and stroke reduction in the ONTARGET trial: benefit beyond blood pressure lowering?. Cerebrovascular Diseases. 2008;26(5):563-4. Full Text: Exclude - not a clinical trial. [pmid: 18936537].
Sever PS, Chang CL. Discordant responses to two classes of drugs acting on the renin-angiotensin system. J Renin Angiotensin Aldosterone Syst. 2001;2(1):25-30. Exclude: Followup < 12 wk. [pmid: 11881062].
Shamshad F, Kenchaiah S, Finn PV, et al. Fatal myocardial rupture after acute myocardial infarction complicated by heart failure, left ventricular dysfunction, or both: The VALsartan in Acute myocardial iNfarcTion Trial (VALIANT). American Heart Journal. 2010;160(1):145-151. Exclude - HTN data not reported separately. [pmid: 20598985].
Shariff N, Dunbar C, Matsumura ME. Relation of pre-event use of inhibitors of the renin-angiotensin system with myocardial infarct size in patients presenting with a first ST-segment elevation myocardial infarction. American Journal of Cardiology. 2010;106(5):646-9. Exclude - HTN data not reported separately. [pmid: 20723639].
Shariff N, Zelenkofske S, Eid S, et al. Demographic determinants and effect of pre-operative angiotensin converting enzyme inhibitors and angiotensin receptor blockers on the occurrence of atrial fibrillation after CABG surgery. BMC Cardiovascular Disorders. 2010;10:7. Exclude - HTN data not reported separately. [pmid: 20141642].
Shobha JC, Kumar TR, Raju BS, et al. Evaluation of efficacy and safety of losartan potassium in the treatment of mild to moderate hypertension as compared to enalapril maleate. J Assoc Physicians India. 2000;48(5):497-500. Exclude: Followup < 12 wk. [pmid: 11273142].
Siiskonen SJ, Breekveldt-Postma NS, Vincze G, et al. Higher persistence with valsartan compared with enalapril in daily practice. Vascular Health & Risk Management. 2007;3(6):1039-44. Full Text: Exclude - no outcomes of interest. [pmid: 18200822].
Sleight P, Redon J, Verdecchia P, et al. Prognostic value of blood pressure in patients with high vascular risk in the Ongoing Telmisartan Alone and in combination with Ramipril Global Endpoint Trial study. see comment. Journal of Hypertension. 2009;27(7):1360-9. Full Text: Exclude - no direct comparison. [pmid: 19506526].
Sleight P. The ONTARGET/TRANSCEND Trial Programme: baseline data. Acta Diabetol. 1. 2005;42:S50-6. Exclude: Baseline data only (no published results as of 8 Dec 2006). [pmid: 15868120].
Smith DH, Dubiel R, Jones M. Use of 24-hour ambulatory blood pressure monitoring to assess antihypertensive efficacy: a comparison of olmesartan medoxomil, losartan potassium, valsartan, and irbesartan. Am J Cardiovasc Drugs. 2005;5(1):41-50. Exclude: Followup < 12 wk. [pmid: 15631537].
Smith DH, Matzek KM, Kempthorne-Rawson J. Dose response and safety of telmisartan in patients with mild to moderate hypertension. J Clin Pharmacol. 2000;40(12 Pt 1):1380-90. Exclude: Followup < 12 wk. [pmid: 11185637].
Smith DH, Neutel JM, Morgenstern P. Once-daily telmisartan compared with enalapril in the treatment of hypertension. Adv Ther. 1998;15:229-40. Exclude: Could not obtain copy.
Sozen AB, Kayacan MS, Tansel T, et al. Drugs with blocking effects on the renin-angiotensin-aldosterone system do not improve endothelial dysfunction long-term in hypertensive patients. Journal of International Medical Research. 2009;37(4):996-1002. Full Text: Exclude - no outcomes of interest. [pmid: 19761681].
Stanton A, Jensen C, Nussberger J, et al. Blood pressure lowering in essential hypertension with an oral renin inhibitor, aliskiren. Hypertension. 2003;42(6):1137-43. Full Text: Exclude - duration < 12 weeks. [pmid: 14597641].
Stergiou GS, Efstathiou SP, Roussias LG, et al. Blood pressure- and pulse pressure-lowering effects, trough:peak ratio and smoothness index of telmisartan compared with lisinopril. J Cardiovasc Pharmacol. 2003;42(4):491-6. Exclude: Followup < 12 wk. [pmid: 14508234].
Stergiou GS, Efstathiou SP, Skeva II, et al. Assessment of drug effects on blood pressure and pulse pressure using clinic, home and ambulatory measurements. J Hum Hypertens. 2002;16(10):729-35. Exclude: Followup < 12 wk. [pmid: 12420198].
Stergiou GS, Skeva II, Baibas NM, et al. Does the antihypertensive response to angiotensin converting enzyme inhibition predict the antihypertensive response to angiotensin receptor antagonism?. Am J Hypertens. 2001;14(7 Pt 1):688-93. Exclude: Followup < 12 wk. [pmid: 11465654].
Stokes GS, Barin ES, Gilfillan KL. Effects of isosorbide mononitrate and AII inhibition on pulse wave reflection in hypertension. Hypertension. 2003;41(2):297-301. Exclude: Followup < 12 wk. [pmid: 12574098].
Strasser RH, Puig JG, Farsang C, et al. A comparison of the tolerability of the direct renin inhibitor aliskiren and lisinopril in patients with severe hypertension. see comment. Journal of Human Hypertension. 2007;21(10):780-7. Full Text: Exclude - duration < 12 weeks. [pmid: 17541390].
Stump CS, Sowers JR. Prevention of type 2 diabetes: Role of the renin-angiotensin-aldosterone system and antihypertensive therapy. Advanced Studies in Medicine. 2006;6(5):231-239. Full Text: Exclude - not a clinical trial.
Suzuki H, Geshi E, Nanjyo S, et al. Inhibitory effect of valsartan against progression of left ventricular dysfunction after myocardial infarctionl - T-VENTURE study. Circulation Journal. 2009;73(5):918-924. Full Text: Exclude - HTN outcomes not reported separately. [pmid: 19346662].
Tai DJ, Lim TW, James MT, et al. Cardiovascular effects of angiotensin converting enzyme inhibition or angiotensin receptor blockade in hemodialysis: A meta-analysis. Clinical Journal of the American Society of Nephrology. 2010;5(4):623-630. Exclude - not clinical trial (SR/MA). [pmid: 20133488].
Takami T, Shigemasa M. Efficacy of various antihypertensive agents as evaluated by indices of vascular stiffness in elderly hypertensive patients. Hypertens Res. 2003;26(8):609-14. Exclude: ACEI not on our list (temocapril). [pmid: 14567499].
Tanabe Y, Kawamura Y, Sakamoto N, et al. Blood pressure control and the reduction of left atrial overload is essential for controlling atrial fibrillation. International Heart Journal. 2009;50(4):445-56. Full Text: Exclude - no outcomes of interest. [pmid: 19609049].
Tanser PH, Campbell LM, Carranza J, et al. Candesartan cilexetil is not associated with cough in hypertensive patients with enalapril-induced cough. Multicentre Cough Study Group. Am J Hypertens. 2000;13(2):214-8. Exclude: Followup < 12 wk. [pmid: 10701823].
Tomiyama H, Motobe K, Zaydun G, et al. Insulin sensitivity and endothelial function in hypertension: a comparison of temocapril and candesartan. Am J Hypertens. 2005;18(2 Pt 1):178-82. Exclude: Followup < 12 wk. [pmid: 15752944].
Totsuka N, Awata N, Takahashi K, et al. A single-center, open-label, randomized, parallel-group study assessing the differences between an angiotensin II receptor antagonist and an angiotensin-converting enzyme inhibitor in hypertensive patients with congestive heart failure: the research for efficacy of angiotensin II receptor antagonist in hypertensive patients with congestive heart failure study. Curr Ther Res Clin Exp. 2003;64(2):81-94. Exclude: Could not obtain copy.
Trenkwalder P, Schaetzl R, Borbas E, et al. Combination of amlodipine 10 mg and valsartan 160 mg lowers blood pressure in patients with hypertension not controlled by an ACE inhibitor/CCB combination. Blood Pressure. 2. 2008;17:13-21. Full Text: Exclude - no direct comparison. [pmid: 19205092].
Triller DM, Evang SD, Tadrous M, et al. First renin inhibitor, aliskiren, for the treatment of hypertension. Pharmacy World and Science. 2008;30(6):741-749. Full Text: Exclude - not a clinical trial. [pmid: 18802783].
Turnbull F, Woodward M, Neal B, et al. Do men and women respond differently to blood pressure-lowering treatment? Results of prospectively designed overviews of randomized trials. European Heart Journal. 2008;29(21):2669-2680. Full Text: Exclude - not a clinical trial. [pmid: 18852183].
Turner CL, Wilkinson IB, Kirkpatrick PJ. Use of antihypertension agents for the suppression of arterial pulse pressure waveforms in patients with intracranial aneurysms. J Neurosurg. 2006;104(4):531-6. Exclude: Followup < 12 wk. [pmid: 16619656].
Turner CL, Wilkinson IB, Kirkpatrick PJ. Use of antihypertension agents for the suppression of arterial pulse pressure waveforms in patients with intracranial aneurysms. see comment. Journal of Neurosurgery. 2006;104(4):531-6. Full Text: Exclude - no outcomes of interest. [pmid: 16619656].
Tylicki L, Rutkowski P, Renke M, et al. Renoprotective effect of small doses of losartan and enalapril in patients with primary glomerulonephritis. Short-term observation. Am J Nephrol. 2002;22(4):356-62. Exclude: Not essential hypertension. [pmid: 12169868].
Uresin Y, Taylor AA, Kilo C, et al. Efficacy and safety of the direct renin inhibitor aliskiren and ramipril alone or in combination in patients with diabetes and hypertension. see comment. Journal of the Renin-Angiotensin-Aldosterone System. 2007;8(4):190-8. Full Text: Exclude - duration < 12 weeks. [pmid: 18205098].
Van Ampting JMA, Hijmering ML, Beutler JJ, et al. Vascular effects of ACE inhibition independent of the renin-angiotensin system in hypertensive renovascular disease: A randomized, double-blind, crossover trial. Hypertension. 2001;37(1):40-5. Exclude: Followup < 12 wk. [pmid: 11208754].
Van Der Niepen P, Woestenburg A, Brie H, et al. Effectiveness of valsartan for treatment of hypertension: Patient profiling and hierarchical modeling of determinants and outcomes (the PREVIEW study). Annals of Pharmacotherapy. 2009;43(5):849-861. Full Text: Exclude - compares ACEIs/drugX vs ARBs/drugY. [pmid: 19351876].
Van Rijn-Bikker PC, Mairuhu G, Van Montfrans GA, et al. Genetic factors are relevant and independent determinants of antihypertensive drug effects in a multiracial population. American Journal of Hypertension. 2009;22(12):1295-1302. Full Text: Exclude - duration < 12 weeks. [pmid: 19779464].
Verdecchia P, Angeli F, Mazzotta G, et al. Aliskiren versus ramipril in hypertension. Therapeutic Advances in Cardiovascular Disease. 2010;4(3):193-200. Exclude - not a clinical study. [pmid: 20418269].
Verdecchia P, Calvo C, Mockel V, et al. Safety and efficacy of the oral direct renin inhibitor aliskiren in elderly patients with hypertension. Blood Pressure. 2007;16(6):381-91. Full Text: Exclude - duration < 12 weeks. [pmid: 18058456].
Verdecchia P, Staessen JA, Achilli A, et al. Randomized study of traditional versus aggressive systolic blood pressure control (Cardio-Sis): Rationale, design and characteristics of the study population. Journal of Human Hypertension. 2008;22(4):243-251. Full Text: Exclude - not a clinical trial. [pmid: 18046432].
Verdecchia P, Staessen JA, Angeli F, et al. Usual versus tight control of systolic blood pressure in non-diabetic patients with hypertension (Cardio-Sis): an open-label randomised trial. The Lancet. 2009;374(9689):525-533. Full Text: Exclude - compares ACEIs/drugX vs ARBs/drugY.
Vidt DG, White WB, Ridley E, et al. A forced titration study of antihypertensive efficacy of candesartan cilexetil in comparison to losartan: CLAIM Study II. J Hum Hypertens. 2001;15(7):475-80. Exclude: Followup < 12 wk. [pmid: 11464257].
Volpe M, Tocci G, Sciarretta S, et al. Angiotensin II receptor blockers and myocardial infarction: an updated analysis of randomized clinical trials. Journal of Hypertension. 2009;27(5):941-6. Full Text: Exclude - not a clinical trial. [pmid: 19381108].
Waeber B, Mourad JJ. Application in the STRATHE trial of a score system to compare the efficacy and the tolerability of different therapeutic strategies in the management of hypertension. Vascular Health & Risk Management. 2008;4(1):249-52. Full Text: Exclude - compares ACEIs/drugX vs ARBs/drugY. [pmid: 18629368].
Weber MA. ONTARGET: questions asked, questions answered. Journal of Clinical Hypertension. 2008;10(6):427-30. Full Text: Exclude - not a clinical trial. [pmid: 18550931].
Weber MA. The 24-hour blood pressure pattern: does it have implications for morbidity and mortality?. Am J Cardiol. 2002;89(2A):27A-33A. Exclude: Trial methods & design (no published results as of 8 Dec 2006).
Weir MR, Bush C, Anderson DR, et al. Antihypertensive efficacy, safety, and tolerability of the oral direct renin inhibitor aliskiren in patients with hypertension: a pooled analysis. Journal of the American Society of Hypertension. 2007;1(4):264-277. Full Text: Exclude - not a clinical trial. [pmid: 20409858].
Weir MR, Smith DH, Neutel JM, et al. Valsartan alone or with a diuretic or ACE inhibitor as treatment for African American hypertensives: relation to salt intake. Am J Hypertens. 2001;14(7 Pt 1):665-71. Exclude: Not ACEI vs. ARB. [pmid: 11465651].
Weir MR, Yeh F, Silverman A, et al. Safety and feasibility of achieving lower systolic blood pressure goals in persons with type 2 diabetes: The SANDS trial. Journal of Clinical Hypertension. 2009;11(10):540-548. Full Text: Exclude - compares ACEIs/drugX vs ARBs/drugY. [pmid: 19817934].
Weiss R, Buckley K, Clifford T. Changing patterns of initial drug therapy for the treatment of hypertension in a Medicaid population, 2001-2005. Journal of Clinical Hypertension. 2006;8(10):706-12. Full Text: Exclude - no outcomes of interest. [pmid: 17028484].
White M, Ross H, Levesque S, et al. Effects of angiotensin-converting enzyme inhibitor versus valsartan on cellular signaling events in heart transplant. Annals of Pharmacotherapy. 2009;43(5):831-9. Full Text: Exclude - no outcomes of interest. [pmid: 19417110].
White WB, Sica DA, Calhoun D, et al. Preventing increases in early-morning blood pressure, heart rate, and the rate-pressure product with controlled onset extended release verapamil at bedtime versus enalapril, losartan, and placebo on arising. Am Heart J. 2002;144(4):657-65. Exclude: Followup < 12 wk. [pmid: 12360162].
Williams B, Lacourciere Y, Schumacher H, et al. Antihypertensive efficacy of telmisartan vs ramipril over the 24-h dosing period, including the critical early morning hours: A pooled analysis of the PRISMA I and II randomized trials. Journal of Human Hypertension. 2009;23(9):610-619. Full Text: Exclude - duplicate publication. [pmid: 19225530].
Woo KT, Lau YK, Chan CM, et al. Angiotensin-converting enzyme inhibitor versus angiotensin 2 receptor antagonist therapy and the influence of angiotensin-converting enzyme gene polymorphism in IgA nephritis. Annals of the Academy of Medicine, Singapore. 2008;37(5):372-6. Full Text: Exclude - no pt has essential HTN.
Xi GL, Cheng JW, Lu GC. Meta-analysis of randomized controlled trials comparing telmisartan with losartan in the treatment of patients with hypertension. American Journal of Hypertension. 2008;21(5):546-52. Full Text: Exclude - not a clinical trial. [pmid: 18437146].
Yang W, Chang J, Kahler KH, et al. Evaluation of compliance and health care utilization in patients treated with single pill vs. free combination antihypertensives. Current Medical Research and Opinion. 2010;26(9):2065-2076. Exclude - HTN data not reported separately. [pmid: 20629600].
Yavuz D, Koc M, Toprak A, et al. Effects of ACE inhibition and AT1-receptor antagonism on endothelial function and insulin sensitivity in essential hypertensive patients. J Renin Angiotensin Aldosterone Syst. 2003;4(3):197-203. Exclude: N < 20. [pmid: 14608527].
Yusuf S, Teo KK, Pogue J, et al. Telmisartan, ramipril, or both in patients at high risk for vascular events. New England Journal of Medicine. 2008;358(15):1547-1559. Full Text: Exclude - only 69% with HTN. [pmid: 18378520].
Zanchetti A, Omboni S, Di Biagio C. Candesartan cilexetil and enalapril are of equivalent efficacy in patients with mild to moderate hypertension. J Hum Hypertens. 2. 1997;11:S57-9. Exclude: Followup < 12 wk. [pmid: 9331009].
Zanchetti A, Omboni S. Comparison of candesartan versus enalapril in essential hypertension. Italian Candesartan Study Group. Am J Hypertens. 2001;14(2):129-34. Exclude: Followup < 12 wk. [pmid: 11243303].
Zimmermann M, Unger T. Challenges in improving prognosis and therapy: the Ongoing Telmisartan Alone and in Combination with Ramipril Global End point Trial programme. Expert Opin Pharmacother. 2004;5(5):1201-8. Exclude: Trial methods & design (no published results as of 8 Dec 2006). [pmid: 15155118].