# Evidence Table

Evidence Table E1 Direct comparator studies of ACEIs, ARBs, and direct renin inhibitors

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Akat, Bapat, Murthy, et al., 2010 #2132 | Geographic location: Miraj, India Study dates: NR Funding source: None Interventions:; 1. Telmisartan 40 mg/d; 2. Enalapril 10 mg/d; Were additional antihypertension medications allowed: NR If Yes to above, was this done: NR Study design: RCT, parallel-group Blinding:; - Patients: NR; - Providers: NR; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: 4 wks of voluntary discontinuation of anti-HTN meds prior to start of study Washout period(s): NA Duration of treatment: 12 weeks Duration of post-treatment followup: NA | Number of patients: N = 80; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 80; - Began treatment: NR; - Completed treatment: NR; - Withdrawals/losses to followup: NR; Age: Mean (SD): NR Median: NR Range: 18-65 Sex (n [%]): Female: NR Male: NR Race/ethnicity (n [%]): NR Baseline blood pressure: BP recorded in a sitting position after 10 minutes of rest Baseline SBP: Telmisartan: 154.72 ± 12.52 Enalapril: 156.05 ± 10.56 Baseline DBP: Telmisartan: 98.22 ± 3.78 Enalapril: 98.34 ± 4.45 Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria:; - Mild to moderate essential hypertension; - Either sex Age 18-65 years; - Either newly diagnosed or had discontinued antihypertensive medication voluntarily for more than 4 weeks; Exclusion criteria:; - On other antihypertensive therapy; - Secondary hypertension; - Impaired liver function (defined as SGOT or SGPT > 2 times normal limit); - History suggestive of obstructive biliary disease, cholestasis or severe hepatic impairment; - Female, of child-bearing age, and not using medically approved contraceptives | | | | | 1) Blood pressure: [underlined: SBP] Baseline: Telmisartan: 154.72 ± 12.52 Enalapril: 156.05 ± 10.56 2 weeks: Telmisartan: 143.16 ± 10.33 Enalapril: 141.6 ± 17.94 4 weeks: Telmisartan: 138.94 ± 9.47 Enalapril: 139.82 ± 9.37 8 weeks: Telmisartan: 133.61 ± 8.29 Enalapril: 133.77 ± 8.53 12 weeks: Telmisartan: 128.33 ± 7.50 Enalapril: 129.31 ± 7.32 [underlined: DBP] Baseline: Telmisartan: 98.22 ± 3.78 Enalapril: 98.34 ± 4.45 2 weeks: Telmisartan: 90.05 ± 1.47 Enalapril: 90.62 ± 1.66 4 weeks: Telmisartan: 88.94 ± 2.36 Enalapril: 89.77 ± 1.26 8 weeks: Telmisartan: 86.44 ± 3.61 Enalapril: 89.37 ± 2.04 12 weeks: Telmisartan: 84.22 ± 3.78 Enalapril: 88.63 ± 1.35 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: Fatigue Telmisartan: 2.77% Enalapril: 2.85% Headache Telmisartan: 2.77% Enalapril: 2.85% Dizziness Telmisartan: 2.77% Enalapril: 2.85% Cough Telmisartan: 0% Enalapril: 11.43% (p < 0.05) 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | | General comments: None Quality assessment: Overall rating: Poor Comments:; - Inadequate reporting of patient recruitment, screening, selection, and retention; - Inadequate reporting of co-interventions; - Statistical analyses not entirely appropriate; Applicability:; - Inadequate description of patient population and clinical settings; - Conducted in India; - No information about co-interventions

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Amerena, Pappas, Ouellet, et al., 2002 #1555 | Geographical location: Multinational, multicenter: Canada (14 sites), Australia (12), Germany (11), Italy (9), Greece (7), Russia (6), Spain (5), Hungary (5), Czech Republic (4), Lithuania (2) Study dates: NR Funding source: NR (one author affiliated with GSK) Interventions:; - Telmisartan (40-80 mg) (n = 264); - Enalapril (10-20 mg) (n = 258); Titrated to higher dose if mean DBP > 90 at wk 6 Study design: RCT, parallel-group Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: Yes for most outcomes except mean seated trough DBP; Was allocation concealment adequate?: NR Baseline/run-in period: 4 wk placebo Duration of treatment: 12 wk Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: 882; - Randomized: 522; - Began treatment: 522; - Completed treatment: 482; - Withdrawals/losses to followup: 40 patients prematurely discontinued treatment (12 due to AEs, reasons for others NR) and 6 more were excluded from ITT analysis (no on-therapy efficacy data); - ITT population: 516 (522-6 patients with no efficacy data); Age: Mean (SD): 52 ± 9.6 Median: NR Range: 23 - 77 Sex (n [%]): Female: 184 (36%) Male: 332 (64%) Race/ethnicity (n [%]): White: 503 (97%) Asian + other: 13 (3%) Baseline blood pressure: Seated unblinded trough (24 hr post-dose) SBP and DBP measured using an automated ABPM SpaceLabs 90207 device; mean of 3 measurements used Baseline values: | | | | | 1) Blood pressure: Change from baseline in mean seated trough BP values at 12 wk (mean values NR): | | | | | | General comments:; - Patients were withdrawn from the study if DBP > 114 or their seated SBP > 200 mmHg at any time; Quality assessment: Overall rating: Fair Comments:; - Statistically significant endpoint not blinded; Applicability:; - No comorbidities discussed; - No clear idea of recruitment strategy; - Run in period on placebo may be selective to patients that got in; - No real baseline information on the patients' other medical issues
Amerena, Pappas, Ouellet, et al., 2002 #1555 | | | | | | | | Telmisartan (n = 250) | | Enalapril (n = 247) | | p
Amerena, Pappas, Ouellet, et al., 2002 #1555
Amerena, Pappas, Ouellet, et al., 2002 #1555 | | | | | | | SBP: | -11.90 | | -10.42 | | p = ns
Amerena, Pappas, Ouellet, et al., 2002 #1555 | | | | | | | DBP: | -9.69 | | -7.67 | | p < 0.02
Amerena, Pappas, Ouellet, et al., 2002 #1555 | | | | | | | DBP response at 12 wk (seated trough DBP < 90 mm Hg and/or a ≥ 10 mm Hg reduction from baseline): Telmisartan: 59% Enalapril: 50% p < 0.05 Also reported 18-24 hr and 24 hr ABPM, daytime, and nighttime BP 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: Any AE: Telmisartan: 76/265 (28.7%) Enalapril: 82/257 (31.9%) AE considered to be drug-related: Telmisartan: 20 (7.5%) Enalapril: 34 (13.2%) 6 serious AEs (treatment group NR), none considered to be drug-related Discontinuation due to AEs: Telmisartan: 4 (1.5%) Enalapril: 8 (3.1%) 6) Specific adverse events:
Amerena, Pappas, Ouellet, et al., 2002 #1555 | | | [underlined: Telmisartan] | | [underlined: Enalapril] | | | | Telmisartan [underlined: (n = 265)] | | Enalapril [underlined: (n = 257)]
Amerena, Pappas, Ouellet, et al., 2002 #1555 | | SBP: | 159.9 ± 12.4 | | 157.7 ± 13.2 | | HA | | 22 (8.3%) | | 18 (7.0%)
Amerena, Pappas, Ouellet, et al., 2002 #1555 | | DBP: | 103.0 ± 6.3 | | 101.6 ± 6.1 | | Cough | | 2 (0.8) | | 23 (8.9)
Amerena, Pappas, Ouellet, et al., 2002 #1555 | | Concurrent medications (n [%]): No other antihypertensives Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria:; - Age > 18; - Mild to moderate essential HTN, 95 ≤ DBP ≤ 114 (or 104 in German and Czech sites); Exclusion criteria:; - Mean SBP ≥ 180; - Secondary HTN; - Uncorrected volume or sodium depletion; - Severe renal impairment, renal artery stenosis, hepatic impairment, biliary obstructive disorders, electrolyte disturbances, primary aldosteronism, or hereditary fructose intolerance; - Known sensitivity to any component of the placebo, telmisartan, or enalapril tablets; - Pregnant women, breastfeeding, or women of childbearing potential not using a approved form of birth control
Amerena, Pappas, Ouellet, et al., 2002 #1555 | | | | | | | Musculoskel pain | | 12 (4.5) | | 8 (3.1)
Amerena, Pappas, Ouellet, et al., 2002 #1555 | | | | | | | Malaise/fatigue | | 6 (2.3) | | 9 (3.5)
Amerena, Pappas, Ouellet, et al., 2002 #1555 | | | | | | | Hypotension | | 3 (1.1) | | 10 (3.9)
Amerena, Pappas, Ouellet, et al., 2002 #1555 | | | | | | | Viral ENT infect | | 8 (3) | | 7 (2.7)
Amerena, Pappas, Ouellet, et al., 2002 #1555 | | | | | | | 7) Persistence/adherence: Compliance assessed by pill count at clinic visit; similar in both groups 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | Geographical location: 92 study centers in Belgium, Canada, Hong Kong, Denmark, Iceland, Slovakia, South Africa, Spain, and USA Study dates: 26 weeks long (no dates given) Funding source: Novartis Pharma AG Interventions: Once daily treatment with:; - Aliskiren (420 patients) 150 mg or; - Ramipril 5mg (422 patients); Up-titration to aliskiren 300 mg or ramipril 10 mg and subsequent addition of HCTZ 12.5 mg and 25 mg were permitted sequentially for patients not achieving adequate BP control at weeks 6, 12, 18, and 21. After 26-week active treatment period, patients were re-randomized equally to either their current regimen or placebo for 4-week withdrawal period. Were additional antihypertension medications allowed: No (except HCTZ, as specified above) Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: Yes; Was allocation concealment adequate?: NR Baseline/run-in period: 4 weeks placebo run-in Washout period(s): 2 weeks Duration of treatment: 26 weeks Duration of post-treatment followup: 4-week withdrawal period | Number of patients: N = 842; - Screened for inclusion: NR; - Eligible for inclusion: 1082; - Randomized: 842; - Began treatment: 842; - Completed treatment: 675; - Withdrawals/losses to followup: 150; Age: Mean (SD): 53.3 ± 11 ≥ 65 years: 127 (15%) Sex (n [%]): Female: 362 (43%) Male: 480 (57%) Race/ethnicity (n [%]): White: 638 (75.8%) Black: 151 (17.9%) Asian: 27 (3.2%) Other: 26 (3.1%) Baseline blood pressure: Aliskiren: Mean sitting SBP: 151.3 ± 11.7 Mean sitting DBP 98.8 ± 3.4 Ramipril: Mean sitting SBP 151.5 ± 11.7 Mean sitting DBP 98.9 ± 3.5 Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): Obese: Aliskiren = 184 (43.8%) Ramipril = 221 (55.4%) Metabolic syndrome: Aliskiren = 171 (40.7%) Ramipril = 183 (43.4%) Diabetes: Aliskiren = 42 (10%) Ramipril = 49 (11.8%) Recruitment setting: NR Inclusion criteria:; - Aged ≥ 18 years; - Hypertension (mean sitting DBP ≥ 90 mmHg and < 110 mmHg); Exclusion criteria:; - Severe HTN (mean sitting DBP ≥ 110 mmHg or mean sitting SBP ≥ 180 mmHg); - History or evidence of secondary HTN; - Known Keith-Wagener grade III or IV hypertensive retinopathy; - Type 1 or type 2 DM with fasting glycosylated hemoglobin (HbA_1c_) > 9% at screening; - History of severe cerebrovascular or cardiovascular disease; - Any condition that may alter the absorption, distribution, metabolism, or excretion of study drugs; - Pregnant or nursing women | | | | | 1) Blood pressure: Aliskiren lowered mean sitting (ms) SBP/ms DBP to 133.7/85.8 mmHg at week 26 endpoint Ramipril lowered ms SBP/ms DBP to 136.4/87.2 mmHg Mean reductions in ms SBP and ms DBP were significantly greater with aliskiren-based therapy. Proportion of patients who had their ms SBP controlled to < 140 mmHg was significantly higher with aliskiren-based therapy (72.5%) than ramipril (64.1%) at week 26 endpoint. The proportion of patients achieving BP < 140/90 mmHg was also significantly higher with aliskiren 61.4% than with ramipril 53.1% Controlled ms SBP < 140 mmHg: 76.8% aliskeren vs. 69.9% ramipril Post hoc analyses for the subgroups of patients with metabolic syndrome, obesity, or diabetes showed that the mean decreases in ms SBP and ms DBP with both aliskiren and ramipril-based therapy were generally similar to those observed in the overall population – though BP reductions with ramipril therapy were slightly larger in the diabetes subgroup than the overall population. Post hoc analysis for the subgroup of patients with stage 2 HTN who completed the 12-week monotherapy phase (n = 88 for aliskiren, n = 87 for ramipril) demonstrated a reduction in SBP and DBP of 22.3 and 12.7 mm Hg, respectively, with aliskiren, and a reduction in SBP and DBP of 18.1/10.2 mm Hg, respectively, with ramipril at 12 weeks. Among this subgroup of patients, aliskiren was non-inferior (p < 0.0001) to ramipril for SBP reduction with non-significant superiority (p = 0.052), and superior (p = 0.043) to ramipril for DBP reduction. 2) Rate of use of a single antihypertensive agent for BP control: Aliskeren: 220/420 (52%) Ramipril: 209/422 (49.5%) Subgroup of patients who received only monotherapy during 26-week treatment period (ITT population aliskiren n = 220, ramipril n = 209): Aliskiren ms SBP/ms DBP 149.8/98.4 to 132.8/85.1 mmHg; ramipril 148.7/98.5 to 135.8/87 mmHg 3) Mortality: One patient died due to mesenteric thrombosis 6 days after discontinuing treatment with ramipril 10 mg plus HCTZ 25mg; the death was not considered related to study medication. 4) Morbidity: NR 5) Safety: | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | Aliskiren | | Ramipril | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | Any AE | | 257 (61.3%) | | 255 (60.4%) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | Any serious AE | | 8 (1.9) | | 6 (1.4) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | Discontinuation due to AE | | 24 (5.7%) | | 20 (4.7%) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | 6) Specific adverse events: Cough reported more than twice as frequently by patients receiving ramipril (9.5%) than aliskiren (4.1%) Cough judged to be treatment-related (ramipril 5.5%, aliskiren 2.1%) Headache more common with aliskiren than ramipril (11.2 vs. 8.3%) but rates of treatment-related headache were low and similar in the two groups (aliskiren 1.4%, ramipril 1.7%) Discontinuation due to cough was more common with ramipril 2.1% than aliskiren 1.0% Only one serious adverse event was considered related to study medications, namely, a case of angioneurotic edema in one patient receiving aliskiren 150 mg, who recovered completely following discontinuation of study medication | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | Aliskiren | | Ramipril | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | Headache | | 47 (11.2) | | 35 (8.3) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | Nasopharyngitis | | 25 (6) | | 26 (6.2) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | Dizziness | | 23 (5.5) | | 20 (4.7) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | Fatigue | | 18 (4.3) | | 15 (3.6) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | Cough | | 17 (4.1) | | 40 (9.5) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | Diarrhea | | 16 (3.8) | | 7 (1.7) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | Peripheral edema | | 16 (3.8) | | 13 (3.1) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | Back pain | | 15 (3.6) | | 13 (3.1) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | Pain in extremity | | 15 (3.6) | | 8 (1.9) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | Bronchitis | | 13 (3.1) | | 4 (0.9) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | URTI | | 12 (2.9) | | 17 (4.0) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | Nausea | | 11 (2.6) | | 8 (1.9) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | Dyspepsia | | 10 (2.4) | | 4 (0.9) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | Sinusitis | | 8 (1.9) | | 10 (2.4) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | Influenza | | 8 (1.4) | | 11 (2.6) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | 7) Persistence/adherence: Aliskiren: 79 (18.8%) discontinued Ramipril: 72 (16.8%) discontinued 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | Aliskiren | | Ramipril | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | Potassium < 3.5 mmol/L | | 22 (5.3) | | 19 (4.6) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | Potassium > 5.5 mmol/L | | 8 (1.9) | | 4 (1.0) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | Potassium ≥ 6.0 mmol/L | | 2 (0.5) | | 1 (0.9) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | BUN > 14.28 mmol/L | | 1 (0.2) | | 1 (0.2) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | Creatinine > 176.8 umol/L | | 0 | | 3 (0.7) | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed
Andersen, Weinberger, Egan, et al., 2008 #130 AND Andersen, Weinberger, Constance, et al., 2009 #1139 AND Andersen, Weinberger, Egan, et al., 2010 #2213 | | | | | | | 13) Proteinuria: NR | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: None Applicability:; - Not enough information about the centers where the studies were performed

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Avanza, El Aouar, and Mill, 2000 #1559 | Geographical location: Vitoria, Brazil Study dates: Unknown Funding source: Merck Sharp & Dhome – supplied meds Interventions:; - Enalapril 20 mg qam + 15 mg qpm (n = 22); - Losartan 100 mg qam + 75 mg qpm (n = 17); - Enalapril 15 mg qam + losartan 100 mg qpm (n = 23); No dose titration; no co-interventions permitted Study design: Non-randomized controlled clinical trial (CCT) Groups assigned sequentially as patients were recruited: Enalapril → enalapril/losartan → losartan Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: Yes (echocardiographers were blinded); Was allocation concealment adequate?: No Baseline/run-in period: 12-day washout of prior meds Duration of treatment: 10 months Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: 90; - Eligible for inclusion: 61; - Allocated: 61; - Began treatment: 61; - Completed treatment: 46; - Withdrawals/losses to followup: 15 (4 due to cough, 4 stopped taking study med, 2 noncompliant, 2 altered medication schedule, 2 treatment failures, 1 acute MI); Age: Mean (SD): 54 ± 4 Sex (n [%]): Female: 19 (41%) Male: 27 (59%) Race/ethnicity (n [%]): “All were white or mulatto” (no numbers given) Baseline blood pressure: Office BP measured using a mercury sphygmomanometer after a 10-min rest in a seated position: Mean baseline values for n = 46 study completers: | | | | | 1) Blood pressure: Mean office SBP values reported in text for 7 mo. Posttreatment office DBP for all timepoints and office SBP for all other timepoints reported only graphically in Figure 1. Mean office SBP at 7 mo: Enalapril (n = 15): 146 ± 1.9 Losartan (n = 15): 146 ± 2.1 Enalapril + losartan (n = 16): 143 ± 1.9 p > 0.05 for between-group comparison of reductions from baseline At 10 mo, SBP values significantly (p < 0.05) higher in the losartan group than in the other 2 groups (shown only graphically in Figure 1) At the end of month 10 “almost all the patients” had BPs in the normal range (SBP < 140 mm Hg, DBP < 90 mm Hg) 2) Rate of use of a single antihypertensive agent for BP control: NA (no other antihypertensives permitted) 3) Mortality: NR 4) Morbidity: 1 patient in the enalapril group had an acute MI 5) Safety: 4/22 patients (18%) in the enalapril group withdrew due to cough 6) Specific adverse events: NR 7) Persistence/adherence: 2/61 patients were noncompliant (both enalapril) 4/61 stopped taking study medication (2 losartan, 2 combination group) 2/61 altered medication schedule (both combination group) 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: Plasma glucose levels (mg%) were in the normal range for all patients and did not change significantly during treatment. There were no significant between-group differences. | | | | | | General comments: None Quality assessment: Overall rating: Poor Comments:; - Poor study design; - Non-randomized, non-blinded; - Small sample size; - Non-responders and non-compliant patients excluded from analysis; - Reported levels of SBP reduction are far greater than that typically reported in most studies; - Missing data, including BP values at 10 months; Applicability:; - Minimal patient characteristics reported; - Black patients excluded; - Analyzed very selected population who completed study, complied with treatment, and responded to treatment (not ITT)
Avanza, El Aouar, and Mill, 2000 #1559 | | | [underlined: SBP] | | [underlined: DBP] | | | | [underlined: Baseline] | | [underlined: 10 mo]
Avanza, El Aouar, and Mill, 2000 #1559 | | Enalapril | 173 ± 2.9 | | 104 ± 1.8 | | Enalapril (n = 15) | | 90 ± 4 | | 90 ± 4
Avanza, El Aouar, and Mill, 2000 #1559 | | Losartan | 170 ± 1.9 | | 103 ± 1.7 | | Losartan (n = 15) | | 93 ± 4 | | 94 ± 4
Avanza, El Aouar, and Mill, 2000 #1559 | | Enalapril + losartan | 173 ± 2.8 | | 104 ± 1.5 | | Enalapril + losartan (n = 16) | | 91 ± 4 | | 91 ± 4
Avanza, El Aouar, and Mill, 2000 #1559 | | 24-hr ABPM also performed using a SpaceLabs 90207 device, with readings every 20 min Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: University clinics Inclusion criteria:; - Both sexes; - Age 40-60; - Resting BP indicating moderate hypertension (by JNC-5) after run-in; - Ambulatory BP confirming moderate hypertension; - Echo criteria for LVH; Exclusion criteria:; - Black race; - Obesity (BMI >30); - Diabetes; - Valvular heart disease; - Secondary hypertension; - History of complications of hypertension (MI or CHF); - Long-term use of corticosteroids, neuroleptics or antidepressants
Avanza, El Aouar, and Mill, 2000 #1559 | | | | | | | 11) LV mass/function: Mean LVMI (g/m^2^)
Avanza, El Aouar, and Mill, 2000 #1559 | | | | | | | | | [underlined: Baseline] | | [underlined: 10 mo]
Avanza, El Aouar, and Mill, 2000 #1559 | | | | | | | Enalapril (n = 15) | | 141 ± 3.9 | | 123 ± 3.6
Avanza, El Aouar, and Mill, 2000 #1559 | | | | | | | Losartan (n = 15) | | 147 ± 3.8 | | 133 ± 2.8
Avanza, El Aouar, and Mill, 2000 #1559 | | | | | | | Enalapril + losartan (n = 16) | | 146 ± 3.0 | | 116 ± 4.0^*^
Avanza, El Aouar, and Mill, 2000 #1559 | | | | | | | ^*^p = 0.011, combination vs. enalapril and vs. losartan at 10 mo; p-values for all other between-group comparisons NS Percent reduction in LVMI from baseline to 10 mo (see Figure 3): Enalapril: 12.4 ± 3.2%^*^ Losartan: 9.1 + 2.1% Enalapril + losartan: 20.5 ± 5.0%^**^ ^*^p < 0.05, enalapril vs. losartan ^**^p < 0.01, combination vs. single treatments 12) Creatinine/GFR: Creatinine levels (mg%) were in the normal range for all patients and did not change significantly during treatment. There were no significant between-group differences.
Avanza, El Aouar, and Mill, 2000 #1559 | | | | | | | | | [underlined: Baseline] | | [underlined: 10 mo]
Avanza, El Aouar, and Mill, 2000 #1559 | | | | | | | Enalapril (n = 15) | | 1.2 ± 0.2 | | 1.2 ± 0.3
Avanza, El Aouar, and Mill, 2000 #1559 | | | | | | | Losartan (n = 15) | | 1.1 ± 0.3 | | 1.2 ± 0.3
Avanza, El Aouar, and Mill, 2000 #1559 | | | | | | | Enalapril +losartan (n = 16) | | 1.2 ± 0.3 | | 1.3 ± 0.3
Avanza, El Aouar, and Mill, 2000 #1559 | | | | | | | 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Barnett, Bain, Bouter, et al., 2004 #1560 | Geographical location: 39 centers in northern Europe (Denmark, Finland, The Netherlands, Norway, Sweden, and the UK) Study dates: NR Funding source: Boehringer Ingelheim Interventions:; - Telmisartan 40 mg daily for 4 weeks, then forced titration to 80 mg daily (n = 120); - Enalapril 10 mg daily for 4 weeks, then forced titration to 20 mg daily (n = 130); Additional antihypertensives (not ACEIs or ARBs) allowed after 2 mo if SBP > 160 or DBP > 100 Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: NR; Was allocation concealment adequate?: Yes Baseline/run-in period: 1 month – received regular antihypertensive meds including an ACEI (which was then stopped at randomization) Duration of treatment: 5 years Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 250; - Began treatment: 250; - Completed treatment: 168; - Withdrawals/losses to followup: 38 telmisartan group (20 due to AEs, 18 for other causes), 44 enalapril group (30 due to AEs, 14 for other causes); Age: Mean (SD): 60.6 (8.8) Median: NR Range: NR Sex (n [%]): Female: 68 (27%) Male: 182 (73%) Race/ethnicity (n [%]): White: 246 (98.4%) Other: 4 (1.6%) Baseline blood pressure: Measured at trough; method of assessment not further described Mean baseline values: | | | | | 1) Blood pressure: Adjusted mean reduction in SBP over 5 yr (last observation carried forward): | | | | | | General comments:; - Primary outcome of study was change in GFR; Quality assessment: Overall rating: Fair Comments:; - Many dropouts; GFR data based on data available in only 216 subjects (103 telmisartan, 113 enalapril); Applicability:; - Patients all with diabetic nephropathy (~80% microalbuminuria, ~20% macroalbuminuria); - Minimal focus on HTN, details of BP assessment not described, and overall targets quite high compared to current recommendations
Barnett, Bain, Bouter, et al., 2004 #1560 | | | | | | | [underlined: Telmisartan] | | | [underlined: Enalapril]
Barnett, Bain, Bouter, et al., 2004 #1560 | | | | | | | 6.9 mm Hg | | | 2.9 mm Hg
Barnett, Bain, Bouter, et al., 2004 #1560 | | | | | | | 95% CI: -8.5 to 0.5 mm Hg Figure 2 demonstrates changes graphically. % of patients with: SBP < 160: 75% SBP < 140: 42% No significant difference between groups. 2) Rate of use of a single antihypertensive agent for BP control: Table 2 gives some information, but is imprecise. Based on figures reported, percentages of patients on monotherapy for hypertension during the study were in the following ranges: Telmisartan: 15-65% Enalapril: 18.5-64.6% 3) Mortality: Deaths: Telmisartan: 6 (3 due to CV events [stroke, MI, or cardiac insufficiency]) Enalapril: 6 (2 due to stroke) 4) Morbidity:
Barnett, Bain, Bouter, et al., 2004 #1560 | | | [underlined: Telmisartan] | | [underlined: Enalapril] | | | | [underlined: Telmisartan] | | [underlined: Enalapril]
Barnett, Bain, Bouter, et al., 2004 #1560 | | SBP | 152.6 ± 16.6 | | 151.6 ± 15.8 | | Stroke | | 6 | | 6
Barnett, Bain, Bouter, et al., 2004 #1560 | | DBP | 85.4 ± 8.8 | | 85.9 ± 7.8 | | CHF | | 9 | | 7
Barnett, Bain, Bouter, et al., 2004 #1560 | | Concurrent medications (n [%]): Diuretics: 130 (52%) Beta-blockers: 98 (39.2%) Calcium channel blockers: 115 (46%) Other antihypertensive agents: 88 (35.2%) Aspirin: 98 (39.2%) Statins: 105 (42%) Comorbidities (n [%]): Duration of diabetes (median [range]): Telmisartan: 8.0 yr (0-25) Enalapril: 8.0 yr (0-37) History of cardiovascular disease: Telmisartan: 59 (49.2%) Enalapril: 63 (48.5%) Recruitment setting: Academic centers in northern Europe Inclusion criteria:; - White or Asian race/ethnicity; - Age 35-80; - Type 2 diabetes treated by diet, diet + oral hypoglycemic drugs (for ≥ 1 year), or insulin preceded by treatment with oral agents (for ≥ 1 year); - For patients treated with insulin, onset of diabetes > age 40 and BMI > 25 at time of diagnosis; - History of mild-to-moderate hypertension (mean seated SBP ≤ 180 mm Hg); - Current resting BP < 180/95 mm Hg after ≥ 3 months of treatment with ACEI prior to study entry; - Normal gross renal morphology for ≥ 12 months; - Urinary albumin excretion rate (mean of 3 consecutive overnight values) of 11-999 μg/min, with 2 values > 10 μg/min; - HbA1c < 12%; - Serum creatinine ≤ 1.6 mg/dL (140 μmol/L); - GFR ≥ 70 mL/min/1.73 m^2^; - Women who were < 60 had to be either surgically sterile or have negative pregnancy test at enrollment; Exclusion criteria [note – some of these are from a separate article describing methods]:; - Renal dysfunction not due to diabetic nephropathy; - Single kidney or known renal artery stenosis; - New York Heart Association functional class II-IV CHF; - Known allergy to study drugs or iohexol; - History of angioedema related to ACEIs
Barnett, Bain, Bouter, et al., 2004 #1560 | | | | | | | Non-fatal MI | | 9 | | 6
Barnett, Bain, Bouter, et al., 2004 #1560 | | | | | | | Incr Cr < 2.3 | | 2 | | 2
Barnett, Bain, Bouter, et al., 2004 #1560 | | | | | | | 5) Safety:
Barnett, Bain, Bouter, et al., 2004 #1560 | | | | | | | | | [underlined: Telmisartan] | | [underlined: Enalapril]
Barnett, Bain, Bouter, et al., 2004 #1560 | | | | | | | Any AE: | | 115 (95.8%) | | 130 (100%)
Barnett, Bain, Bouter, et al., 2004 #1560 | | | | | | | AE leading to study discontinuation: | | 20 (17%) | | 30 (23%)
Barnett, Bain, Bouter, et al., 2004 #1560 | | | | | | | 6) Specific adverse events: See 4) above. Note that patients with know history of angioedema related to ACEIs were excluded. 7) Persistence/adherence: NR 8) Lipid levels: Pre-study levels recorded, post-study not given although stated “there were no changes in routine hematologic or blood chemical values in either group.” 9) Progression to type 2 diabetes: NA (all had type 2 diabetes with micro/macroalbuminuria) 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: See Fig 1 & Table 3 for details. Mean change from baseline (last observation carried forward):
Barnett, Bain, Bouter, et al., 2004 #1560 | | | | | | | | | Telmisartan (n = 103) | | Enalapril (n = 113) | Change (95% CI)
Barnett, Bain, Bouter, et al., 2004 #1560
Barnett, Bain, Bouter, et al., 2004 #1560 | | | | | | | GFR | | -17.5 | | -15.0 | -2.6 (-7.1, 2.0)
Barnett, Bain, Bouter, et al., 2004 #1560 | | | | | | | | | Telmisartan (n = 116) | | Enalapril (n = 128) | Change (95% CI)
Barnett, Bain, Bouter, et al., 2004 #1560
Barnett, Bain, Bouter, et al., 2004 #1560 | | | | | | | Creat | | 0.10 | | 0.10 | 0 (-0.66, 0.65)
Barnett, Bain, Bouter, et al., 2004 #1560 | | | | | | | 13) Proteinuria: Mean change from baseline (last observation carried forward):
Barnett, Bain, Bouter, et al., 2004 #1560 | | | | | | | | | Telmisartan (n = 115) | | Enalapril (n = 125) | Change (95% CI)
Barnett, Bain, Bouter, et al., 2004 #1560
Barnett, Bain, Bouter, et al., 2004 #1560 | | | | | | | UAE^*^ | | 1.03 | | 0.99 | 1.04 (0.71, 1.51)
Barnett, Bain, Bouter, et al., 2004 #1560 | | | | | | | ^*^UAE = urinary albumin excretion (ratio)

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Black, Graff, Shute, et al., 1997 #1561 | Geographical location: NR, but likely U.S. in Illinois, Florida, Texas, or Oregon Study dates: NR Funding source: NR, but one author each affiliated with GFI Pharmaceutical Services and Ciba-Geigy Corporation Interventions:; - Valsartan 80 mg with titration to 160 mg once daily (n = 177); - Valsartan 80 mg with titration to 80 mg twice daily (n = 187); - Lisinopril 10 mg with titration to 20 mg once daily (n = 187); - Placebo (n = 183); Dose titration and co-interventions: Titration allowed after 4 wk for patients with mean seated DBP ≥ 90 and no symptoms of orthostatic hypotension; no co-interventions allowed Study design: RCT, parallel-group Stratified by age Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: Yes; Was allocation concealment adequate?: NR Baseline/run-in period: 2- to 4-wk placebo run-in Duration of treatment: 12 wk Duration of post-treatment followup: NR | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 734; - Began treatment: 734; - Completed treatment: 644; - Withdrawals/losses to followup: 90 (“most” due to AEs or unsatisfactory therapeutic response); Age: Mean (SD): 53.5 Median: NR Range: NR Sex (n [%]): Female: 39% Male: 61% Race/ethnicity (n [%]): White: 81% Black: 14% Other: 4% Baseline blood pressure: Trough seated BP measured 3 times each visit after 5-min rest using mercury sphygmomanometer Mean baseline values (± SD): | | | | | 1) Blood pressure: Mean post-treatment BP values NR Primary outcome = least mean square change in DBP from baseline (all randomized patients, using last available posttreatment BP measurement): Valsartan 80/160: -8.29 mm Hg Valsartan 80/80×2: -8.67 Lisinopril 10/20: -9.97 p = NS Results for change in SBP reported to be comparable (quantitative data NR) Per-protocol results for 12 wk also reported, but only graphically (Figure 2) BP response rates (mean DBP < 90 or ≥ 10 decrease from baseline; all randomized patients, using last available posttreatment BP measurement): Valsartan 80/160: 44.1% Valsartan 80/80×2: 48.7% Lisinopril: 10/20: 57.2% p = 0.012 for valsartan 80/160 vs. lisinopril p = NS for valsartan 80/80×2 vs. lisinopril 2) Rate of use of a single antihypertensive agent for BP control: No additional antihypertensives allowed 3) Mortality: NR 4) Morbidity: NR 5) Safety: Any AE: Valsartan (any dose): 62.6% Lisinopril (either dose): 58.3% AEs considered to be drug-related: Valsartan: 22.8% Lisinopril: 27.8% Serious AEs and/or withdrawals due to AEs: Valsartan: 14/364 (3.8%) Lisinopril: 8/187 (4.3%) Drug-related AEs leading to withdrawal: Valsartan: 7 (headache 3, lightheadedness 1, shortness of breath 1, rash 1, fatigue 1) Lisinopril: 6 (cough 3, chest pain 1, nausea/dizziness 1, fatigue 1) 6) Specific adverse events: | | | | | | General comments: Population not well specified, randomization not specified Quality assessment: Overall rating: Fair Comments:; - Population not well specified; - Method of randomization not described; - Potential confounders/comorbidities not discussed; - Some important outcomes not assessed; did not report unadjusted posttreatment DBP and SBP values; Applicability:; - Setting not specified, study centers not reported; - Unclear how patients recruited; - Exclusion criteria vague on what “clinically significant” means
Black, Graff, Shute, et al., 1997 #1561 | | | [underlined: SBP] | | [underlined: DBP]
Black, Graff, Shute, et al., 1997 #1561 | | Valsartan 80/160 | 153.64 ± 11.07 | | 100.81 ± 4.41 | | | | Valsartan (n = 364) | | Lisinopril (n = 187)
Black, Graff, Shute, et al., 1997 #1561 | | Valsartan 80/80×2 | 154.27 ± 14.95 | | 101.66 ± 4.83
Black, Graff, Shute, et al., 1997 #1561 | | Lisinopril 10/20 | 153.93 ± 14.94 | | 100.99 ± 4.45 | | Headache | | 7.7% | | 3.2%
Black, Graff, Shute, et al., 1997 #1561 | | Concurrent medications (n [%]): NR, but no BP lowering meds allowed Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria:; - Age 21-80 yr; - Stage I-III diastolic HTN (seated DBP ≥ 95 and ≤ 115 after placebo run-in period); Exclusion criteria:; - Symptomatic CHF, MI, hypertensive encephalopathy, or CV accident < 6 mo; - 2^nd^ or 3^rd^ degree heart block; - Angina; - Clinically relevant arrhythmias; - Clinically significant valvular disease; - Significant hepatic disease; - Significant renal disease; - Insulin-dependent diabetes; - Women of childbearing age not using contraception
Black, Graff, Shute, et al., 1997 #1561
Black, Graff, Shute, et al., 1997 #1561 | | | | | | | Viral infection | | 0.3% | | 0%
Black, Graff, Shute, et al., 1997 #1561
Black, Graff, Shute, et al., 1997 #1561 | | | | | | | URI | | 0.5% | | 0%
Black, Graff, Shute, et al., 1997 #1561
Black, Graff, Shute, et al., 1997 #1561 | | | | | | | Fatigue | | 2.2% | | 3.7%
Black, Graff, Shute, et al., 1997 #1561
Black, Graff, Shute, et al., 1997 #1561 | | | | | | | Back pain | | 0.3% | | 0%
Black, Graff, Shute, et al., 1997 #1561
Black, Graff, Shute, et al., 1997 #1561 | | | | | | | Diarrhea | | 1.6% | | 2.1%
Black, Graff, Shute, et al., 1997 #1561
Black, Graff, Shute, et al., 1997 #1561 | | | | | | | Cough | | 1.1% | | 8.0%
Black, Graff, Shute, et al., 1997 #1561
Black, Graff, Shute, et al., 1997 #1561 | | | | | | | Dizzy | | 1.1% | | 3.7%
Black, Graff, Shute, et al., 1997 #1561
Black, Graff, Shute, et al., 1997 #1561 | | | | | | | Sinusitis | | 0.3% | | 1.1%
Black, Graff, Shute, et al., 1997 #1561
Black, Graff, Shute, et al., 1997 #1561 | | | | | | | 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570 | Geographical location: Throughout US Study dates: Jul 1995 to Jun 1996; subsequent study reported followup to Jun 2000 Funding source: Merck & Co., Inc. Interventions: ARB (n = 567) ACE inhibitor (n = 5842) CCB (n = 5094) Beta-blocker (n = 4994) Thiazide diuretic (n = 5226) Study design: Retrospective cohort study Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: No; Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: NA Duration of post-treatment followup: 4 yr | Number of patients:; - Screened for inclusion: 1.3 to 1.6 million; - Eligible for inclusion: NA; - Randomized: NA; - Began treatment: 21,723; - Completed treatment: NA; - Withdrawals/losses to followup: 6548 lost by 4-year followup; Age: Mean (SD): 56 (NR) Median: NR Range: 35-71 Sex (n [%]): Female: 12,148 (55.9%) Male: 9575 (44.1%) Race/ethnicity (n [%]): NR Baseline blood pressure: NR Concurrent medications (n [%]): 0 [0%] (not allowed) Comorbidities (n [%]): NR (attempted to eliminate subjects with comorbid conditions based on concurrent prescriptions) Recruitment setting: Enrollees in pharmacy benefit management program which includes HMO, Blue Cross-Blue Shield, and union, corporate, and government clients Inclusion criteria:; - Patients filling first antihypertensive drug prescription in one of 5 classes (ARB, ACEI, CCB, beta-blocker, thiazide) during study period; - No prescription filled for any antihypertensive drug in prior 12 mo; Exclusion criteria:; - Prescription for nitrate, antiarrhythmic, digoxin, warfarin, loop diuretic, or certain antimigraine drugs; - Concurrent prescriptions for two or more antihypertensive drug classes (including combination products); - Incomplete data on age and sex | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: Based on prescription refill on or within 3 mo after 1-yr anniversary of initial prescription 1-year data: | | | | | | General comments:; - The large sample size and representative population of the PBM database are strengths of the study, but rating is downgraded because of lack of specificity regarding hypertensive diagnosis and comorbidity, as well as no dose info; correlation between dose and BP response and change in prescription; - Reasons for discontinuing therapy are not captured (ineffective? adverse events?); - ARBs were introduced just 1 year before the study period, suggesting that prescribing patterns may have been in flux – may not be representative of current patterns; Quality assessment: Overall rating: Fair Comments:; - Appears to be well done study for administrative database; Applicability:; - Lack of clinical data on subjects means that baseline BP data, BP response, actual comorbidities are unknown
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570 | | | | | | | Drug | | Continued | | Switched | D/c'd
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570 | | | | | | | ARB | | 64% | | 7% | 29%
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570 | | | | | | | ACEI | | 58% | | 9% | 33%
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570 | | | | | | | CCB | | 50% | | 9% | 41%
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570 | | | | | | | Beta-B | | 43% | | 7% | 50%
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570 | | | | | | | Thiaz | | 38% | | 6% | 56%
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570 | | | | | | | In multivariable analysis:; - Age ≥ 65 years was associated with higher persistence than age between 40 and 64 years (OR, 0.79; 95% CI, 0.74 to 0.84; p = 0.001) and age < 40 years (OR, 0.32; 95% CI, 0.29 to 0.35; p = 0.0001); - Dosing more than once daily was associated with lower persistence than once-daily dosing (OR, 1.40; 95% CI, 1.29 to 1.52; p = 0.0001); 4-year data:
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570 | | | | | | | Drug | | Continued | | Switched | D/c'd
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570 | | | | | | | ARB | | 50.8% | | 16.5% | 32.7%
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570 | | | | | | | ACEI | | 46.5% | | 18.9% | 34.6%
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570 | | | | | | | CCB | | 40.7% | | 19.3% | 40.0%
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570 | | | | | | | Beta-B | | 34.7% | | 12.7% | 52.6%
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570 | | | | | | | Thiaz | | 16.4% | | 32.6% | 51.0%
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570
Bloom, 1998 #1562 and Conlin, Gerth, Fox, et al., 2001 #1570 | | | | | | | - Persistence with ARB (92% losartan) was higher than persistence with CCBs, beta-blockers or thiazides (p < 0.03), but not higher than ACEI (p = 0.095).; - Persistence was higher among women than men, and higher among patients ≥ 65 years of age than those < 65 years of age; 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Bourgault, Senecal, Brisson, et al., 2005 #1563 | Geographical location: Saskatchewan, Canada (database including > 90% of provincial residents) Study dates: Jan 1994-Sep 1999 Funding source: Merck Frosst Canada, Ltd. Interventions: Number of patients with data for at least 180 days: ARBs (n = 1002) ACEIs (n = 7104) Beta-blockers (n = 3989) CCBs (n = 2400) Diuretics (n = 6831) Study design: Retrospective cohort study Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: No; Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: NR Duration of post-treatment followup: Mean length of followup in ARB and ACEI groups = 1.85 yr | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: 21,326; - Randomized: NA; - Began treatment: NA; - Completed treatment: NA; - Withdrawals/losses to followup: NA; Age (ARBs and ACEIs): Mean: 57.6 Median: NR Range: NR Sex (ARBs and ACEIs; %): Female: 45.7% Male: 54.3% Race/ethnicity (n [%]): NR Baseline blood pressure: NR Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: Population-based prescription drug database Inclusion criteria:; - ICD-9 code diagnosis of hypertension (401, 402, 403, 404, or 4-digit codes included in these categories); - Age 18-80 yr; - New dispensed antihypertensive med between Jan 1997 and Sep 1999; - Antihypertensive prescribed was ARB, ACEI, beta-blocker, CCB, or diuretic; Exclusion criteria:; - Prescribed more than one antihypertensive agent at treatment initiation | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: Sample sizes at various timepoints: | | | | | | General comments:; - Cohort studied overlaps with that studied in Marentette, Gerth, Billings, et al., 2002 (#12830); includes fewer total patients, but many more taking ARBs; Quality assessment: Overall rating: Fair Comments:; - Non-random allocation to drugs; - No data on comparability of patients on ACEIs versus ARBs; - Funded by pharmaceutical company; Applicability:; - Study period soon after introduction of ARBs; early use may not reflect current use patterns
Bourgault, Senecal, Brisson, et al., 2005 #1563 | | | | | | | | | [underlined: ARBs] | | [underlined: ACEIs]
Bourgault, Senecal, Brisson, et al., 2005 #1563 | | | | | | | 1 year | | 463 | | 3456
Bourgault, Senecal, Brisson, et al., 2005 #1563 | | | | | | | 2 years | | 148 | | 1541
Bourgault, Senecal, Brisson, et al., 2005 #1563 | | | | | | | 3 years | | 5 | | 265
Bourgault, Senecal, Brisson, et al., 2005 #1563 | | | | | | | Persistence defined as continuously refilling a prescription for any antihypertensive drug within 90 days of previous dispensing (assumed to last 15-30 days), regardless of switches across drug classes and add-on therapies. Cumulative persistence:
Bourgault, Senecal, Brisson, et al., 2005 #1563 | | | | | | | | | [underlined: ARBs] | | [underlined: ACEIs]
Bourgault, Senecal, Brisson, et al., 2005 #1563 | | | | | | | 1 year | | 66% | | 59%
Bourgault, Senecal, Brisson, et al., 2005 #1563 | | | | | | | 2 years | | 56% | | 47%
Bourgault, Senecal, Brisson, et al., 2005 #1563 | | | | | | | 3 years | | 53% | | 40%
Bourgault, Senecal, Brisson, et al., 2005 #1563 | | | | | | | Similar results were observed after controlling for age and sex, which were not explicitly noted as being statistically significant. Note: “Persistence” includes combinations and switches; in essence, what is being modeled is failure to discontinue. 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Burke, Sturkenboom, Lu, et al., 2006 #1565 | Geographical location: 694 general practices widely distributed across the UK (less coverage in Scotland and inner London) Study dates: Jan 1991 – Mar 2002 Funding source: Merck & Co., Inc. Interventions: Numbers reported below are the % of patients given a drug from the specified class as their first prescription and the total number of “drug class episodes,” respectively ACEI (12.2%; 36,386) ARB (0.5%; 5184) α-antagonist (1.1%; 7823) Beta-blocker (27.4%; 54,973) CCB (12.5%; 41,019) Potassium-sparing diuretic (0.2%; 1831) Thiazide (42.0%; 71,331) Miscellaneous monotherapy (0.3%; 4681) Combination (3.7%; NA) Study design: Retrospective cohort study Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: No; Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: NA Duration of post-treatment followup: 4 yr | Number of patients:; - Screened for inclusion: > 9 million; - Eligible for inclusion: 109,454; - Randomized: NA; - Began treatment: 109,454; - Completed treatment: NA; - Withdrawals/losses to followup: NA; Age: Mean (SD): 60.6 (13.4) Median: NR Range: | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: Discontinuation was analyzed based on a Kaplan-Meier analysis of time until 90+ days passed without a refill. Investigators also performed a Cox regression using the same outcome variable and controlling for various patient factors (age, number of previous antihypertensive drug classes, calendar year of antihypertensive therapy initiation, pretreatment SBP, duration of hypertension, smoking). The results of this modeling are substantially similar to the unadjusted analysis presented immediately below. Cumulative discontinuation rates: | | | | | | General comments:; - Outcomes of interest were analyzed on the basis of the number of drug-class episodes (223,228), not number of patients (109,454); Quality assessment: Overall rating: Poor Comments:; - Non-random allocation to drugs; - Time period of study includes considerable period before ARBs were available; allocation of patients to ACEIs versus ARBs may as a result be biased; - No measurement, reporting, or adjustment for potential confounders; - No data on comparability of patients on ACEIs versus ARBs; Applicability:; - UK location and different health system may affect use rates/patient characteristics; - Study period soon after introduction of ARBs; early use may not reflect current use patterns; - Specific ACEIs and ARBs not identified; - Diabetics excluded
Burke, Sturkenboom, Lu, et al., 2006 #1565 | | < 50 | | 22.4% | | | | | [underlined: 1 yr] | [underlined: 2 yr] | [underlined: 3 yr] | [underlined: 4 yr]
Burke, Sturkenboom, Lu, et al., 2006 #1565 | | 50-59 | | 25.1% | | | ACEIs | | 37.8% | 48.0% | 54.8% | 60.4%
Burke, Sturkenboom, Lu, et al., 2006 #1565 | | 60-69 | | 25.5% | | | ARBs | | 29.4% | 41.3% | 50.3% | 57.8%
Burke, Sturkenboom, Lu, et al., 2006 #1565 | | ≥ 70 | | 27.0% | | | α-antag | | 44.7% | 56.5% | 64.4% | 69.9%
Burke, Sturkenboom, Lu, et al., 2006 #1565 | | Sex (n [%]): Female: 56.5% Male: 43.5% Race/ethnicity (n [%]): NR Baseline blood pressure: Mean SBP (± SD): 173.5 ± 21.1 Mean DBP (± SD): 99.7 ± 27.3 Concurrent medications (n [%]): NR; patients with pre-existing diabetes prescription excluded Comorbidities (n [%]): NR; patients with pre-existing diabetes diagnosis excluded Recruitment setting: UK General Practice Research Database. Contains information (demographic descriptors, information from GP visits, GP prescription data [used to generate written prescriptions], diagnoses from specialist referrals and hospital admissions, and lab results) on > 9 million patients. Inclusion criteria:; - Age ≥ 18; - New physician diagnosis of hypertension between 1 Jan and 31 Dec 2001 (“new” diagnosis = no hypertension diagnoses prior to 1 Jan 1991 and no antihypertensive prescription within 1 year of new diagnosis); Exclusion criteria:; - Diabetes diagnosis or diabetes prescription before antihypertensive prescription
Burke, Sturkenboom, Lu, et al., 2006 #1565 | | | | | | | BB | | 44.0% | 54.3% | 61.2% | 66.7%
Burke, Sturkenboom, Lu, et al., 2006 #1565 | | | | | | | CCB | | 41.2% | 51.5% | 58.8% | 64.7%
Burke, Sturkenboom, Lu, et al., 2006 #1565 | | | | | | | K-diuretic | | 64.1% | 74.9% | 81.1% | 84.9%
Burke, Sturkenboom, Lu, et al., 2006 #1565 | | | | | | | Thiazide | | 43.9% | 55.4% | 63.1% | 69.3%
Burke, Sturkenboom, Lu, et al., 2006 #1565 | | | | | | | Misc | | 62.8% | 75.0% | 81.1% | 84.8%
Burke, Sturkenboom, Lu, et al., 2006 #1565 | | | | | | | Switching was defined only for the subset of patients that discontinued their first line antihypertensive:
Burke, Sturkenboom, Lu, et al., 2006 #1565 | | | | | | | ACEIs | | | 44.2%
Burke, Sturkenboom, Lu, et al., 2006 #1565 | | | | | | | ARBs | | | 36.5%
Burke, Sturkenboom, Lu, et al., 2006 #1565 | | | | | | | α-antag | | | 38.2%
Burke, Sturkenboom, Lu, et al., 2006 #1565 | | | | | | | BB | | | 44.8%
Burke, Sturkenboom, Lu, et al., 2006 #1565 | | | | | | | CCB | | | 43.4%
Burke, Sturkenboom, Lu, et al., 2006 #1565 | | | | | | | K-diuretic | | | 30.4%
Burke, Sturkenboom, Lu, et al., 2006 #1565 | | | | | | | Thiazide | | | 44.6%
Burke, Sturkenboom, Lu, et al., 2006 #1565 | | | | | | | Misc | | | 25.9%
Burke, Sturkenboom, Lu, et al., 2006 #1565 | | | | | | | Even though the investigators' modeling controlled for various patient characteristics, it was not possible to determine which of these characteristics were predictive of persistence. 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Celik, Iyisoy, Kursaklioglu, et al., 2005 #1566 | Geographical location: NR (author based in Turkey) Study dates: NR Funding source: NR Interventions:; - Ramipril 10 mg (n = 50); - Telmisartan 80 mg telmisartan (n = 50); Study design: RCT, parallel-group Blinding:; - Patients: NR; - Providers: NR; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: NR Duration of treatment: 6 months Duration of post-treatment followup: NR | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 100; - Began treatment: NR; - Completed treatment: NR; - Withdrawals/losses to followup: NR; Age: Mean (SD): 51.79 ±6.01 Median: NR Range: NR Sex (n [%]): Female: 44 (44%) Male: 56 (56%) Race/ethnicity (n [%]): NR Baseline blood pressure: BP measured 3 times after a 10-min resting period using a standard mercury sphygmanometer; mean of 3 measurements used | | | | | 1) Blood pressure: At 6 months, n = 50 each group: | | | | | | General comments: None Quality assessment: Overall rating: Poor Comments:; - Significant missing data – timing, funding of study, the number screened, the number that completed treatment; - Study and assessment were not blinded; may lead to bias; - No data on safety/adverse events; Applicability:; - Many common conditions excluded; - No information on number screened or recruitment setting; - No data on race/ethnicity of subjects
Celik, Iyisoy, Kursaklioglu, et al., 2005 #1566 | | | | | | | | | [underlined: Telmisartan] | | [underlined: Ramipril] | [underlined: p-value]
Celik, Iyisoy, Kursaklioglu, et al., 2005 #1566 | | | | | | | SBP | | 133.5 ± 9.48 | | 130.4 ± 13.39 | 0.18
Celik, Iyisoy, Kursaklioglu, et al., 2005 #1566 | | | | | | | DBP | | 81.4 ± 6.06 | | 80.2 ± 7.75 | 0.39
Celik, Iyisoy, Kursaklioglu, et al., 2005 #1566 | | | | | | | 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: Atrial fibrillations occurred in 4 patients in enalapril arm and 2 patients telmisartan arm 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: LVEF
Celik, Iyisoy, Kursaklioglu, et al., 2005 #1566 | | | [underlined: Telmisartan] | | [underlined: Ramipril] | | | | [underlined: Telmisartan] | | [underlined: Ramipril]
Celik, Iyisoy, Kursaklioglu, et al., 2005 #1566 | | SBP | 155.9 ± 6.75 | | 154.3 ± 5.44 | | Before | | 61.58 ± 2.06 | | 61.96 ± 1.87
Celik, Iyisoy, Kursaklioglu, et al., 2005 #1566 | | DBP | 96.4 ± 6.47 | | 94.7 ± 5.83 | | After | | 61.70 ± 1.54 | | 61.94 ± 1.40
Celik, Iyisoy, Kursaklioglu, et al., 2005 #1566 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): DM: 17 (17%) Family history of premature CAD: 19 (19%) Smoking: 26 (26%) Recruitment setting: NR Inclusion criteria: 100 newly diagnosed hypertensive patients without the below exclusions Exclusion criteria:; - Secondary or malignant hypertension; - Chronic obstructive lung disease; - Atrial fibrillation, flutter, or any other atrial tachyarrhythmia's with 1 month; - History of anti-arrythmic drugs, including digoxin, within 1 month; - Hyperthyroidism; - Severe valvular disease of hemodynamic significance; - History of sensitivity to use of ACEIs or ARBs; - Pregnancy or nursing; - MI or cerebrovascular accident within 6 months; - History of proven coronary artery disease; - Concurrent therapy with medication that could affect blood pressure; - Severe renal or hepatic failure | | | | | 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | Geographical location: Multicenter trial: 17 centers in Spain Study dates: NR Funding source: Sanofi-Synthelabo Spain Interventions: Doses (titrated doses if DBP ≥ 90 after 4 or 8 weeks of treatment):; - Irbesartan 150 mg/d (300 mg); n = 111, dose titration in 80 (72%); - Enalapril 10 mg/d (20 mg); n =115, dose titration in 88 (76.5%); Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: NR; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: 3-wk single-blind placebo phase; patients with mean daytime DBP < 85 mm Hg during this period were excluded Duration of treatment: 12 weeks Duration of post-treatment followup: 24 hours after last dose of study medication | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: 295; - Randomized: 238; - Began treatment: 238; - Completed treatment: 226; - Withdrawals/losses to followup: 12 (5 due to AEs, 4 lost to followup, 3 due to lack of efficacy); Age: Mean (SD): 52.7 ± 10.6 yr Median: NR Range: 22-73 Sex (n [%]): Female: 52% Male: 48% Race/ethnicity (n [%]): 100% white Baseline blood pressure: Clinic BP using mercury sphygmo-manometer: After resting for 10 minutes in seated position; non-dominant arm supported and cuff arm at heart level. 3 successive readings at 3 min intervals, mean of 3 values recorded. | | | | | 1) Blood pressure: Posttreatment seated trough BP values not reported ABPM results: 24-hr BP at 12 wk: | | | | | | General comments:; - Baseline 24-hour SBP significantly higher in irbesartan group (mean 4 mm p = 0.003); Quality assessment: Overall rating: Fair Comments:; - Very little baseline information; - Randomization process not described; - Patients who failed treatment (BP ≥ 180/110 despite full-dose treatment) excluded (n = 3); Applicability:; - All white patients; - Recruitment setting not clearly described; - Process of inclusion of study centers not described; - Comorbid conditions not described: they were “excluded” but list of criteria not mentioned
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | | | Irbesartan [underlined: (n = 111)] | | Enalapril [underlined: (n = 115)]
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | SBP | | 128.8 ± 13.8 | | 127.2 ± 11.1
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | DBP | | 79.9 ± 8.8 | | 80.5 ± 8.1
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | Baseline and 12-wk mean BPs also reported for ambulatory daytime BP (= average 10 a.m. to 8 p.m.) and nighttime BP (average 12 – 6 a.m.) Mean reductions in 24-hr ABPM BP:
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | [underlined: Irbesartan] | | [underlined: Enalapril] | | | | Irbesartan [underlined: (n = 111)] | | Enalapril [underlined: (n = 115)]
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | SBP | 160.3 ± 14.1 | | 158.2 ± 13.8 | | SBP | | 14.7 ± 14.7 | | 12.6 ± 13.1
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | DBP | 101.6 ± 4.7 | | 102.0 ± 5.2 | | DBP | | 9.4 ± 8.5 | | 8.8 ± 8.5
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | 24-hr ABPM using a non-invasive automated oscillometric device (Spacelabs 90207); cuff placed on non-dominant arm, BP recorded at 20-min intervals automatically for 24 hr | | | | | Between-group p-value NS Mean reductions in seated trough BP:
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | Irbesartan [underlined: (n = 115)] | | Enalapril [underlined: (n = 123)] | | | | Irbesartan (n = 111) | | Enalapril (n = 115)
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | SBP | 144.2 ± 11.5 | | 140.1 ± 11.9
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | DBP | 89.9 ± 6.3 | | 89.6 ± 7.9 | | SBP | | 19.0 ± 14.1 | | 17.5 ± 14.0
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | Concurrent medications (n [%]): No other antihypertensives or any other drugs with effects on the cardiovascular system permitted Comorbidities (n [%]): NR; patients with severe concomitant disease excluded Recruitment setting: NR Inclusion criteria: Mild-moderate hypertension (clinic DBP 90-109 mm Hg on ≥ 3 occasions, SBP 140-179 mm Hg or uncontrolled hypertension (BP ≥ 140/90) despite monotherapy with antihypertensive drugs other than ACE inhibitors or ARBs Exclusion criteria:; - Renal impairment (Ser Cr > 1.5 mg/dL), papilledema, or evidence of coronary heart disease or cardiac failure during the previous 3 months; - Severe concomitant disease; - Women who were pregnant or of childbearing potential
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | DBP | | 12.7 ± 8.8 | | 12.4 ± 7.4
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | Between-group p-value NS Seated trough BP – response rates: 36% (40/111) of patients treated with irbesartan and 34.8% (40/115) of those treated with enalapril achieved strict BP control (clinic BP < 140/90 at 12 wk). Response rates based on the clinic criterion (DBP reduction of ≥ 10 mm Hg at 12 wk) were 64.0% (71/11) and 67.8% (78/115), respectively. 24-hr ABPM – response rates: 40.5% (45/111) of patients with irbesartan and 33.9% (39/115) with enalapril achieved strict BP control (daytime BP < 130/85 at 12 wk), with no significant difference between groups. Response rates (reduction in 24-hr DBP of ≥ 5 mm Hg at 12 wk independent of clinic values) were 71.2% (79/111) and 71.3% (82/115), respectively. 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety:
Coca, Calvo, Garcia-Puig, et al., 2002 #1569
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | | | Irbesartan n (%) | | Enalapril n (%)
Coca, Calvo, Garcia-Puig, et al., 2002 #1569
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | Any AE | | 46 (40) | | 63 (51.2)
Coca, Calvo, Garcia-Puig, et al., 2002 #1569
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | Discontinued due to AEs | | 2 (1.7) | | 3 (2.4)
Coca, Calvo, Garcia-Puig, et al., 2002 #1569
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | AEs deemed probably related to treatment were less frequent with irbesartan than with enalapril (9.2% vs. 24.6%, p = 0.026) Risk of AEs deemed probably related to treatment: 2.6 times higher in those treated with enalapril (OR 2.6, 95% CI 1.1 to 6.1) Discontinued due to AEs in irbesartan group (n = 2): GI disturbance, nausea, vomiting Discontinued due to AEs in enalapril group (n = 3): skin rash, persistent cough 6) Specific adverse events: Most common AEs (> 5% in either group):
Coca, Calvo, Garcia-Puig, et al., 2002 #1569
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | | | Irbesartan n (%) | | Enalapril n (%)
Coca, Calvo, Garcia-Puig, et al., 2002 #1569
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | Nervous system | | 22 (19.1) | | 33 (26.8)
Coca, Calvo, Garcia-Puig, et al., 2002 #1569
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | Fatigue, back pain, fever | | 16 (13.9) | | 10 (8.1)
Coca, Calvo, Garcia-Puig, et al., 2002 #1569
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | GI system | | 12 (10.4) | | 8 (6.5)
Coca, Calvo, Garcia-Puig, et al., 2002 #1569
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | Headache | | 11 (9.6) | | 18 (14.6)
Coca, Calvo, Garcia-Puig, et al., 2002 #1569
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | Dizziness | | 9 (7.8) | | 17 (13.8)
Coca, Calvo, Garcia-Puig, et al., 2002 #1569
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | Cardiovascular system | | 8 (7.0) | | 9 (7.3)
Coca, Calvo, Garcia-Puig, et al., 2002 #1569
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | Palpitations | | 7 (6.1) | | 8 (6.5)
Coca, Calvo, Garcia-Puig, et al., 2002 #1569
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | Upper resp tract | | 4 (3.5) | | 18 (14.6)
Coca, Calvo, Garcia-Puig, et al., 2002 #1569
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | Cough | | 1 (0.9) | | 10 (8.1)
Coca, Calvo, Garcia-Puig, et al., 2002 #1569
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | Skin disorders | | - | | 5 (4.1)
Coca, Calvo, Garcia-Puig, et al., 2002 #1569
Coca, Calvo, Garcia-Puig, et al., 2002 #1569 | | | | | | | 7) Persistence/adherence: Compliance with treatment (assessed by pill counts at each visit) similar in two groups: 98.3% in patients treated with irbesartan and 98.4% in those treated with enalapril Irbesartan once daily better tolerated than enalapril once daily 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Cotter, Oliveira, Cunha, et al., 2008 #66 | Geographical location: Guimaraes, Portugal Study dates: Jan 2004-June 2005 Funding source: NR Interventions: Treatment with either ACEIs (n = 40) or ARBs (n = 31) ACEIs used were lisinopril (20 mg/d) or ramipril (10 mg/d) ARBS used were irbesartan (300 mg/d) or valsartan (160 mg/d) Were additional antihypertension medications allowed: Yes as long not an ACEI (in the ARB group) or an ARB (in the ACEI group) If Yes to above, was this done: At discretion of clinician/investigator Study design: Other – prospective longitudinal observational study Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: No; Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: 12 months (total) Duration of post-treatment followup: 12 months (total) | Number of patients: N = 71; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: NA; - Began treatment: 71; - Completed treatment: 71; - Withdrawals/losses to followup: 0; Age: Mean (SD): 57.4 ± 13.7 Sex (n [%]): Female: 39 (54.9%) Male: 32 (45.1%) Race/ethnicity (n [%]): NR Baseline blood pressure: Automatic Omron M4-1 device with patient resting seated for at least 10 minutes, measured 3 times during visit and mean of last two measurements taken as blood pressure value ARB baseline: SBP 148.5 ± 16.3 DBP 86.7 ± 15.2 ACEI baseline: SBP: 154.5 ± 20.7 DBP 85.8 ± 13.6 Concurrent non hypertension medications (n [%]): States that there were no differences between the groups in the mean of prescribed antihypertensive drugs, statins, or antiplatelets, or in the presence in each group of other classes of antihypertensive drugs prescribed Comorbidities (n [%]): No significant differences in comorbidities other than BMI (higher in the ARB treatment group) and glomerular filtration rate (higher in ARB group) Specific numbers listed below: | | | | | 1) Blood pressure: 12-month followup – note that all patients are on ACE or ARB at baseline, so these findings should not be combined with other studies reporting blood pressure lowering outcome ARB: SBP: 148.5 ± 20.5 DBP: 89.1 ± 13.5 ACEI baseline: SBP: 149.3 ± 19.1 DBP: 87.5 ± 10.0 2) Rate of use of a single antihypertensive agent for BP control: States that there were no differences between the groups in the mean of prescribed antihypertensive drugs, statins, or antiplatelets, or in the presence in each group of other classes of antihypertensive drugs prescribed 3) Mortality: None 4) Morbidity: | | | | | | General comments:; - Does not provide information on how long patients were on treatment prior to observational study; - Goal of study is evaluate the evolution of urinary albumin excretion in hypertensive patients with microalbuminuria undergoing ACEI or ARB treatment; Quality assessment: Overall rating: Fair Comments: None Applicability:; - All patients were on “ongoing treatment” with an ACE or ARB at baseline, so blood pressure changes do not reflect a new treatment start; - Does not discuss crossovers or whether treatment was discontinued for any reason; - Does not describe adverse events related to treatment
Cotter, Oliveira, Cunha, et al., 2008 #66
Cotter, Oliveira, Cunha, et al., 2008 #66 | | Comorbidity | | ARB | | ACEI | Comorbidity | | ARB | | ACEI
Cotter, Oliveira, Cunha, et al., 2008 #66
Cotter, Oliveira, Cunha, et al., 2008 #66 | | Diabetes | | 25 (80.6%) | | 27 (67.5%) | BMI | | 30.9 ± 5.6 | | 27.9 ± 4.2^*^
Cotter, Oliveira, Cunha, et al., 2008 #66
Cotter, Oliveira, Cunha, et al., 2008 #66 | | Smokers | | 7 (22.5%) | | 3 (7.5%) | GFR (MDRD) | | 75.9 ± 19.8 | | 64.2 ± 18.8^*^
Cotter, Oliveira, Cunha, et al., 2008 #66
Cotter, Oliveira, Cunha, et al., 2008 #66 | | BMI | | 30.8 ± 5.7 | | 27.7 ± 4.0^*^ | GFR (Cockcroft-Gault) | | 96.1 ± 41.8 | | 72.1 ± 27.8^*^
Cotter, Oliveira, Cunha, et al., 2008 #66
Cotter, Oliveira, Cunha, et al., 2008 #66 | | GFR (MDRD) | | 76.6 ± 20.7 | | 66 ± 18.7^*^ | HbA1c | | 7.5 ± 1.8 | | 7.7 ± 1.6
Cotter, Oliveira, Cunha, et al., 2008 #66
Cotter, Oliveira, Cunha, et al., 2008 #66 | | GFR (Cockcroft-Gault) | | 97.8 ± 39.9 | | 73.9 ± 27.8^*^ | Stroke | | 5 (16.1%) | | 9 (22.5%)
Cotter, Oliveira, Cunha, et al., 2008 #66
Cotter, Oliveira, Cunha, et al., 2008 #66 | | HbA1c | | 7.2 ± 1.9 | | 7.8 ± 1.7 | IHD | | 3 (9.7% | | 5 (12.5%)
Cotter, Oliveira, Cunha, et al., 2008 #66
Cotter, Oliveira, Cunha, et al., 2008 #66 | | Stroke | | 5 (16.1%) | | 8 (20%) | HF | | 4 (12.9%) | | 5 (12.5%)
Cotter, Oliveira, Cunha, et al., 2008 #66
Cotter, Oliveira, Cunha, et al., 2008 #66 | | IHD | | 2 (6.5% | | 5 (12.5%) | PAD | | 7 (22.6%) | | 7 (17.5%)
Cotter, Oliveira, Cunha, et al., 2008 #66
Cotter, Oliveira, Cunha, et al., 2008 #66 | | HF | | 3 (9.7%) | | 5 (12.5%) | 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: See above table (under “Morbidity”) 11) LV mass/function: NR 12) Creatinine/GFR: See table above (under “Morbidity”) 13) Proteinuria: NR
Cotter, Oliveira, Cunha, et al., 2008 #66
Cotter, Oliveira, Cunha, et al., 2008 #66 | | PAD | | 6 (16.1%) | | 5 (12.5%)
Cotter, Oliveira, Cunha, et al., 2008 #66
Cotter, Oliveira, Cunha, et al., 2008 #66 | | ^*^P < 0.05. Recruitment setting: Outpatient hypertension clinic of a hospital serving a population of about 300,000 Inclusion criteria: Study included all patients who attended hospital HTN clinic during study dates with confirmed HTN and microalbumineria and an estimated creatinine clearance of ≥ 29 mL/min as determined by the simplified MDRD equation and who were undergoing treatment with either ACEIs or ARBs (but not both). Subjects treated with ACEIs were never treated with ARBs and vice versa. Exclusion criteria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Cuspidi, Muiesan, Valagussa, et al., 2002 #1478 | Geographical location: 36 sites in Italy, France, Germany Study dates: NR Funding source: Takeda Italia Interventions:; - Candesartan 8-16 mg qd (n = 115); - Enalapril 10-20 mg qd (n = 124); Dose titration/co-interventions:; - Higher dose of study drug used after 4 wk if BP not controlled (≥ 140/90 mmHg or DBP reduced < 10 mmHg and SBP < 20%); - After 4 additional wk, if BP not controlled, HCTZ 12.5 mg added and titrated up to 25 mg as needed; Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: Yes; Was allocation concealment adequate?: Yes Baseline/run-in period: 2- to 4-week run-in with single-blind placebo, previous antihypertensive treatments withdrawn Duration of treatment: 48 weeks Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: 304; - Eligible for inclusion: 239; - Randomized: 239; - Began treatment: 239; - Completed treatment: 182; - Withdrawals/losses to followup: 57 (19 due to AEs, 12 withdrew consent, 14 lack of efficacy, 12 “other”); - ITT population = 196; - Per-protocol population = 145; Age: Mean (SD): 52.9 Median: NR Range: NR Sex (n [%]): Female: 74/196 (38%) Male: 122/196 (62%) Race/ethnicity (n [%]): NR Baseline blood pressure: Seated trough BP measured using a mercury sphygmomanometer; 3 readings taken at 1-min intervals after patient seated for 5 min of rest. Mean of 3 readings used. | | | | | 1) Blood pressure: BP was measured at the end of placebo period and at 4, 8, 12, 24, 36, and 48 weeks Mean post-treatment BP values NR Mean changes in SBP and DBP from baseline to last available timepoint (ITT population): No significant difference between the two treatments (no quantitative data or statistical tests shown) Similar results (no significant between-group differences) for mean changes in SBP and DBP at 24 and 48 wk in the per-protocol population (no quantitative data or statistical tests shown) The percentage of patients achieving BP normalization (defined as < 140/90 mmHg): Candesartan: 60.4% Enalapril: 60.0% No statistical testing shown; not clear whether ITT or per-protocol population 2) Rate of use of a single antihypertensive agent for BP control: ITT analysis (n = 196 patients) Patients receiving study drug alone (with no HCTZ): Candesartan: 54.3% Enalapril: 45.8% Per-protocol analysis (n = 145 patients) Patients receiving study drug alone (with no HCTZ): Candesartan: 61.0% Enalapril: 53.4% 3) Mortality: NR 4) Morbidity: NR 5) Safety: There were no serious AEs Adverse events: | | | | | | General comments:; - Emphasis on a non-biased approach and interpretation of results; Quality assessment: Overall rating: Fair Comments:; - Would have been compelling if article included the mean BP measurements taken at 4, 8, 12, 24, 36, and 48 wk; - May be error in randomization, as female low in the enalapril group (34% vs. 42% in candesartan group); Applicability:; - No data on race/ethnicity of subjects; - Restricted to patients with LVH
Cuspidi, Muiesan, Valagussa, et al., 2002 #1478
Cuspidi, Muiesan, Valagussa, et al., 2002 #1478 | | | | | | | | | N (%) | | Withdrawals (n)
Cuspidi, Muiesan, Valagussa, et al., 2002 #1478
Cuspidi, Muiesan, Valagussa, et al., 2002 #1478 | | | | | | | Candesartan | | 16 (14%) | | 6
Cuspidi, Muiesan, Valagussa, et al., 2002 #1478
Cuspidi, Muiesan, Valagussa, et al., 2002 #1478 | | | | | | | Enalapril | | 24 (19%) | | 13
Cuspidi, Muiesan, Valagussa, et al., 2002 #1478
Cuspidi, Muiesan, Valagussa, et al., 2002 #1478 | | | | | | | 6) Specific adverse events: Cough occurred in 9% of enalapril patients and in 3% of candesartan patients 7) Persistence/adherence: Compliance measured by counting return tablets; no results reported. 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: LV mass estimated by Devereux's formula and normalized for body surface LVMI (g/m^2^) measurements by echocardiographic and Doppler (ITT population):
Cuspidi, Muiesan, Valagussa, et al., 2002 #1478 | | | Candesartan (n = 91) | | Enalapril (n = 105)
Cuspidi, Muiesan, Valagussa, et al., 2002 #1478 | | | | | | | | | Baseline | | Treatment (last available timepoint)
Cuspidi, Muiesan, Valagussa, et al., 2002 #1478 | | SBP | 163.1 ± 9.7 | | 162.4 ± 8.9
Cuspidi, Muiesan, Valagussa, et al., 2002 #1478 | | DBP | 101.5 ± 3.9 | | 101.0 ± 4.4 | | Candesartan (n = 91) | | 141.0 ± 24.1 | | 126.0 ± 32.4
Cuspidi, Muiesan, Valagussa, et al., 2002 #1478 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria:; - Age 25-70 yr; - Hypertension (SBP 150-200 mm Hg and DBP 95-115 mm Hg at end of placebo run-in period); - LVH (LVMI > 120g/m^2^ in men and LVMI > 100g/m^2^ in women); Exclusion criteria:; - Adequate M-mode echo cardiogram not obtained; - Clinical or echocardiographic evidence of significant valvular disease; - Coronary heart disease; - CHF; - Dilated LV chamber (end diastolic diameter > 60 mm)
Cuspidi, Muiesan, Valagussa, et al., 2002 #1478
Cuspidi, Muiesan, Valagussa, et al., 2002 #1478 | | | | | | | Enalapril (n = 105) | | 143.4 ± 27.5 | | 130.1 ± 29.3
Cuspidi, Muiesan, Valagussa, et al., 2002 #1478
Cuspidi, Muiesan, Valagussa, et al., 2002 #1478 | | | | | | | The decrease in LV mass was accomplished by substantial reduction in interventricular septum and posterior wall thickness in both treatment groups. 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
De Rosa, Cardace, Rossi, et al., 2002 #1571 | Geographical location: Naples, Italy Study dates: NR Funding source: NR Interventions:; - Enalapril 5-20 mg (n = 24); - Losartan 12.5-50 mg (n = 26); Dose titration:; - Enalapril started at 5 mg daily, titrated q 7 days, as tolerated, to 10 mg and 20 mg daily if DBP ≥ 90; - Losartan started at 12.5 mg daily, titrated q 7 days, as tolerated, to 25 mg and 50 mg daily if DBP ≥ 90; No co-interventions permitted Study design: RCT, parallel-group Blinding:; - Patients: Yes (double-dummy); - Providers: Yes; - Assessors of outcomes: Yes; Was allocation concealment adequate?: NR Baseline/run-in period: 2-wk placebo run-in Duration of treatment: 3 years Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 50; - Began treatment: 50; - Completed treatment: 42; - Withdrawals/lost to followup: 8 (3 due to AEs, 2 lost to followup, 2 non-responders, 1 other); Age: For randomized group n = 50; - Mean (SD): 52 yrs (7.7); - Median: NR; - Range: NR; For analyzed group completing study n = 42; - Mean: 55 (SD not reported); - Range: 52-62; Sex (n [%]): (#s given are for analyzed 42 pts) Female: 21 (50%) Male: 21 (50%) Race/ethnicity (n [%]): NR Baseline blood pressure: Trough seated BP measured using a standard mercury sphygmomanometer after 5 min rest; average of 3 readings taken at 1-min intervals | | | | | 1) Blood pressure: Seated trough mean difference in BP (95% CI) at 3 yrs: p value – NS Losartan (n = 22) Pre- 155/103 Post- 140/92 Mean diff SBP -14.5mmHg (-22.6, -6.4) Mean diff DBP -10.5mmHg (-13.5, -7.6) Enalapril (n = 20) Pre- 159/102 Post- 144/91 Mean diff SBP -14.6 (-27.4, -1.7) Mean diff DBP -11.4 (-14.8, -8.1) 2) Rate of use of a single antihypertensive agent for BP control: NA (no other antihypertensive meds permitted) 3) Mortality: NR 4) Morbidity: No quantitative data reported. Number of patients assessed unclear for most measures. QOL: “battery-of-scales” QOL instrument at baseline and after 12 wk of therapy. There were no statistical differences between the two therapies in the domains of general health, sexual functioning, or for the other scales of quality of life. For symptom bother, there was no between-group difference in HA or flushing, but there was a significantly higher incidence of “bother due to cough” in the enalapril patients than in losartan patients after 3 years of treatment, regardless of whether the symptom was present at baseline (12% vs. 2%; p = 0.01). 5) Safety: Withdrawals due to AEs: Losartan: 0/26 Enalapril: 3/24 (12.5%) 6) Specific adverse events: In patients completing treatment (n = 42), frequency of cough was:; - Losartan 2%; - Enalapril 12% (p = 0.01); 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: LV mass index change pre-/post- (baseline to 3 yr) using 2-D echocardiogram (g/m^2^): Change | | | | | | General comments:; - 2/26 pts in losartan group withdrew due to ineffective therapy and were excluded from analysis; 0/24 were excluded from enalapril for this reason. This biases BP results in losartan's favor.; Quality assessment: Overall rating: Fair Comments: See comments above and below. Applicability:; - Small number of patients from single center in Italy; - Minimal information on patient characteristics; - Analyzed according to treatment completion and excluded those in whom therapy was ineffective
De Rosa, Cardace, Rossi, et al., 2002 #1571 | | | | | | | [underlined: Pre-] | | [underlined: Post-] | | [underlined: (95% CI)]
De Rosa, Cardace, Rossi, et al., 2002 #1571 | | | | | | | Losartan: | | 176 ± 24 124 | | -52 (-110.5, 32)
De Rosa, Cardace, Rossi, et al., 2002 #1571 | | | | | | | Enalapril | | 170 ± 19 129 | | -41(-90.3, 21.9)
De Rosa, Cardace, Rossi, et al., 2002 #1571 | | | | | | | P-value for between-group difference NR 12) Creatinine/GFR: GFR measured by renal scintigraphy at baseline and 3 yr (mL/min ± SD):
De Rosa, Cardace, Rossi, et al., 2002 #1571 | | | [underlined: Losartan] | | [underlined: Enalapril]
De Rosa, Cardace, Rossi, et al., 2002 #1571 | | SBP | 155 ± 17 | | 159 ± 19 | | | | Losartan | | Enalapril
De Rosa, Cardace, Rossi, et al., 2002 #1571 | | DBP | 103 ± 4 | | 102 ± 5
De Rosa, Cardace, Rossi, et al., 2002 #1571 | | Concurrent medications (n [%]): NR; no non-study antihypertensives permitted Comorbidities (n [%]): See Exclusion criteria (below); otherwise NR Recruitment setting: Outpatient clinic Inclusion criteria:; - Essential HTN; - WHO stage II (SBP >140 and/or DBP > 90); Exclusion criteria:; - Sig cardiovascular, cerebrovascular, renal, or hepatic disease.; - Recent MI; - Secondary HTN; - “Clinicially significant lab abnormalities”
De Rosa, Cardace, Rossi, et al., 2002 #1571 | | | | | | | Baseline | | 96.5 ± 32.3 | | 94.8 ± 31.1
De Rosa, Cardace, Rossi, et al., 2002 #1571
De Rosa, Cardace, Rossi, et al., 2002 #1571 | | | | | | | 3 yr | | 108.6 ± 31.1 | | 99.8 ± 19.6
De Rosa, Cardace, Rossi, et al., 2002 #1571
De Rosa, Cardace, Rossi, et al., 2002 #1571 | | | | | | | P-value | | < 0.005 | | 0.085
De Rosa, Cardace, Rossi, et al., 2002 #1571
De Rosa, Cardace, Rossi, et al., 2002 #1571 | | | | | | | 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Degli Esposti, Degli Esposti, Valpiani, et al., 2002 #1573 (1-year results) and Degli Esposti, Sturani, Di Martino, et al., 2002 #1572 (3-year results) | Geographical location: Ravenna, Italy (databases of a local health unit) Study dates: Jan-Dec 1997 Funding source: Local health unit and Merck Sharp & Dohme Italia S.p.A. Interventions: ACEIs (n = 4986) ARBs (n = 317) CCBs (n = 4680) Diuretics (n = 4341) Beta-blockers (n = 2459) Study design: Retrospective cohort study Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: No; Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: NR Duration of post-treatment followup: Data reported for 1 and 3 years | Number of patients:; - Screened for inclusion: 19,124; - Eligible for inclusion: 16,783; - Randomized: NA; - Began treatment: NA; - Completed treatment: NA; - Withdrawals/losses to followup: NA; Age (ACEIs and ARBs): Mean: 56.1 Median: NR Range: 20-105 Sex (ACEIs and ARBs, %]): Female: 52.6% Male: 47.4% Race/ethnicity (n [%]): NR Baseline blood pressure: NR Concurrent medications (n [%]): NR Comorbidities (n [%]): | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: Persistence described under heading of “continuing,” “switching,” and “discontinuing” therapy; arbitrary minimum of 273 days used as cutoff. Continuing defined as persisting with original drug therapy, even if combined with an agent from another class. Switching defined as persisting with drug treatment, but switching to a drug of a different class. Discontinuing defined as giving up drug therapy altogether. 1-year data: | | | | | | General comments:; - Small sample sizes for ARBs at 1 year (n = 317) and 3 years (n = 198); Quality assessment: Overall rating: Fair Comments:; - Non-random allocation to drugs; - No data on comparability of patients on ACEIs versus ARBs; - Funded by pharmaceutical company; Applicability:; - Study period soon after introduction of ARBs; early use may not reflect current use patterns
Degli Esposti, Degli Esposti, Valpiani, et al., 2002 #1573 (1-year results) and Degli Esposti, Sturani, Di Martino, et al., 2002 #1572 (3-year results) | | | [underlined: ACEIs] | | [underlined: ARBs] | | | Continue | Switch | | Discontinue
Degli Esposti, Degli Esposti, Valpiani, et al., 2002 #1573 (1-year results) and Degli Esposti, Sturani, Di Martino, et al., 2002 #1572 (3-year results) | | Cardiopathy | 1.3% | | 0.9% | | ACEIs | 30.7% | 9.4% | | 59.9%
Degli Esposti, Degli Esposti, Valpiani, et al., 2002 #1573 (1-year results) and Degli Esposti, Sturani, Di Martino, et al., 2002 #1572 (3-year results) | | Diabetes | 2.1% | | 1.3% | | ARBs | 33.4% | 24.6% | | 42.0%
Degli Esposti, Degli Esposti, Valpiani, et al., 2002 #1573 (1-year results) and Degli Esposti, Sturani, Di Martino, et al., 2002 #1572 (3-year results) | | Asthma/COPD | 1.2% | | 1.3% | | Persistence was related to older age, taking medication for heart disease or diabetes, history of previous hospitalizations for CV events, and presence of ≥ 2 comorbidities 3-year results: No quantitative data reported. Persistence was related to older age, young general practitioner, male general practitioner, and male sex. ARBs had better persistence throughout the followup period, but precise estimates could not be derived from Figure 2. 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Degli Esposti, Degli Esposti, Valpiani, et al., 2002 #1573 (1-year results) and Degli Esposti, Sturani, Di Martino, et al., 2002 #1572 (3-year results) | | Previous hosp for CV disease | 7.9% | | 8.2%
Degli Esposti, Degli Esposti, Valpiani, et al., 2002 #1573 (1-year results) and Degli Esposti, Sturani, Di Martino, et al., 2002 #1572 (3-year results) | | ≥ 2 comorbidities | 1.6% | | 3.2%
Degli Esposti, Degli Esposti, Valpiani, et al., 2002 #1573 (1-year results) and Degli Esposti, Sturani, Di Martino, et al., 2002 #1572 (3-year results) | | Recruitment setting: Database of local health unit Inclusion criteria:; - New user of antihypertensive drug (not prescribed any antihypertensive drugs during previous 12 mo); - Age ≥ 20 years; - Received first prescription for a diuretic, beta-blocker, CCB, ARB, or ACEI during study period; Exclusion criteria:; - Prescriptions for ≥ 2 antihypertensive agents or for a combination agent involving ≥ 2 classes; - History of ≥ 3 prescriptions for cardiovascular, antidiabetes, or antiasthmatic/COPD drugs over previous 12 mo

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Delea, Taneja, Moynahan, et al., 2007 #196 | Geographical location: 70 health plan databases across US Study dates: Jan 1, 1997-Dec 31, 2003 Funding source: Novartis Pharmaceuticals Corporation Interventions: Valsartan (n = 6645) Lisinopril (n = 17,320) Extended-release metoprolol (not described further here) Were additional antihypertension medications allowed: Yes (but not other study drug) If Yes to above, was this done: At discretion of clinician/investigator Study design: Other – retrospective study Blinding:; - Patients: NA; - Providers: NA; - Assessors of outcomes: NA; Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: Maximum follow up was approximately 70 months in both groups Duration of post-treatment followup: NA | Number of patients: N = 29,357; - Screened for inclusion: 1,482,294; - Eligible for inclusion: 244,512; - Randomized: NA; - Began treatment: 244,512; - Completed treatment: NA; - Withdrawals/losses to followup: NA; Age: Mean (SD): 54.8 ± 9.6 (valsartan), 55.4 ± 10.1 (lisinopril) Sex (n [%]): Female: 3808 (57.3%) valsartan 8850 (51.1%) lisinopril Male: 2837 (42.7%) valsartan 8470 (48.9%) lisinopril Race/ethnicity (n [%]): NR Baseline blood pressure: NR Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): Using Deyo-Charlson index Mean: Valsartan 0 ± 0.8 Lisinopril 0 ± 0.9 Anemia: Valsartan: 239 (3.6%) Lisinopril: 600 (3.5%) Atrial fibrillation or flutter: Valsartan: 35 (0.5%) Lisinopril: 123 (0.7%) Coronary heart disease: Valsartan: 181 (2.7%) Lisinopril: 455 (2.6%) Cerebrovascular disease: Valsartan: 25 (0.4%) Lisinopril: 104 (0.6%) Diabetes: Valsartan: 659 (9.9%) Lisinopril: 3052 (17.6%) Hypercholesterolemia: Valsartan: 1923 (28.9%) Lisinopril: 5340 (30.8%) Obesity: Valsartan: 151 (2.3%) Lisinopril: 467 (2.7%) Peripheral arterial disease: Valsartan: 26 (0.4%) Lisinopril: 100 (0.6%) Proteinuria: Valsartan: 16 (0.2%) Lisinopril: 57 (0.3%) Renal disease: Valsartan: 32 (0.5%) Lisinopril: 85 (0.5%) Valvular heart disease: Valsartan: 8 (0.1%) Lisinopril: 25 (0.1%) Recruitment setting: Pharmetrics Patient Centric Database Inclusion criteria: All persons in the database with two or more outpatient prescriptions for valsartan, lisinopril, or extended-release metoprolol and two or more prior claims with a diagnosis of hypertension Exclusion criteria:; - History of major cardiovascular or renal events (diagnosis of MI, stroke, heart failure, ventricular arrhythmias, or cardiac arrest; coronary revascularization procedure; diagnosis of renal failure; or dialysis or kidney transplantation); - Use of other antihypertensive medications except diuretics during the 12 months before treatment with valsartan, lisinopril, or extended-release metoprolol | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: None 4) Morbidity: In multivariate analysis, valsartan was associated with a reduced risk of a major cardiovascular or renal event compared with lisinopril although this finding was not statistically significant (HR, 0.89; 95% CI 0.74–1.07; P = 0.1987) Cardiovascular or renal event: Valsartan: 162 (2.4%) Lisinopril: 632 (3.6%) HR (95% CI) valsartan vs. lisinopril (univariate analysis): 0.77 (0.65–0.92) Multivariate analysis: 0.89 (0.74–1.07) Cardiovascular event: Valsartan: 137 (2.1%) Lisinopril: 513 (3.0%) HR (95% CI) valsartan vs. lisinopril (univariate analysis): 0.81 (0.67–0.97) Multivariate analysis: 0.92 (0.75–1.13) Myocardial infarction: Valsartan: 33 (0.5%) Lisinopril: 103 (0.6%) HR (95% CI) valsartan vs. lisinopril (univariate analysis): 0.98 (0.66–1.45) Multivariate analysis: 1.15 (0.75–1.74) Stroke: Valsartan: 31 (0.5%) Lisinopril: 90 (0.5%) HR (95% CI) valsartan vs. lisinopril (univariate analysis): 1.10 (0.73–1.66) Multivariate analysis: 1.27 (0.82–1.96) Heart failure: Valsartan: 56 (0.8%) Lisinopril: 289 (1.7%) HR (95% CI) valsartan vs. lisinopril (univariate analysis): 0.58 (0.44–0.78) Multivariate analysis: 0.69 (0.51–0.93) Ventricular arrhythmias: Valsartan: 11 (0.2%) Lisinopril: 35 (0.2%) HR (95% CI) valsartan vs. lisinopril (univariate analysis): 0.97 (0.49–1.91) Multivariate analysis: 0.81 (0.39–1.69) Cardiac arrest: Valsartan: 4 (0.1%) Lisinopril: 8 (0.0%) HR (95% CI) valsartan vs. lisinopril (univariate analysis): 1.66 (0.50–5.56) Multivariate analysis: 1.95 (0.47–8.08) Revascularization: Valsartan: 46 (0.7%) Lisinopril: 148 (0.9%) HR (95% CI) valsartan vs. lisinopril (univariate analysis): 0.94 (0.67–1.31) Multivariate analysis: 1.13 (0.80–1.61) CABG: Valsartan: 15 (0.2%) Lisinopril: 55 (0.3%) HR (95% CI) valsartan vs. lisinopril (univariate analysis): 0.84 (0.48–1.50) Multivariate analysis: 1.12 (0.62–2.05) PCI: Valsartan: 33 (0.5%) Lisinopril: 97 (0.6%) HR (95% CI) valsartan vs. lisinopril (univariate analysis): 1.02 (0.68–1.51) Multivariate analysis: 1.15 (0.76–1.75) Renal event: Valsartan: 33 (0.5%) Lisinopril: 170 (1.0%) HR (95% CI) valsartan vs. lisinopril (univariate analysis): 0.60 (0.42–0.88) Multivariate analysis: 0.73 (0.49–1.08) Chronic renal failure: Valsartan: 30 (0.5%) Lisinopril: 155 (0.9%) HR (95% CI) valsartan vs. lisinopril (univariate analysis): 0.60 (0.41–0.90) Multivariate analysis: 0.70 (0.46–1.07) Dialysis: Valsartan: 4 (0.1%) Lisinopril: 29 (0.2%) HR (95% CI) valsartan vs. lisinopril (univariate analysis): 0.46 (0.16–1.30) Multivariate analysis: 0.73 (0.25–2.15) Kidney transplant: Valsartan: 0 (0.0%) Lisinopril: 0 (0.0%) HR (95% CI) valsartan vs. lisinopril (univariate analysis): NA Multivariate analysis: NA Unstable angina: Valsartan: 49 (0.7%) Lisinopril: 133 (0.8%) HR (95% CI) valsartan vs. lisinopril (univariate analysis): 1.12 (0.80–1.55) Multivariate analysis: 1.08 (0.76–1.53) Development of diabetes: Valsartan: 189 (3.2%) Lisinopril: 583 (4.1%) HR (95% CI) valsartan vs. lisinopril (univariate analysis): 0.86 (0.73–1.02) Multivariate analysis: 0.81 (0.68–0.96) Development of renal disease: Valsartan: 19 (0.3%) Lisinopril: 103 (0.6%) HR (95% CI) valsartan vs. lisinopril (univariate analysis): 0.54 (0.33–0.88) Multivariate analysis: 0.87 (0.52–1.46) 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | | General comments: Does not describe effect on BP; focus is on cardiovascular and renal events Quality assessment: Overall rating: Fair Comments: None Applicability:; - Retrospective analysis limited in ability to overcome selection bias; - Does not describe BP or safety/adverse events; - Does not describe persistence; - Followup time is unclear

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | Geographical location: Pavia, Italy Study dates: NR Funding source: NR Interventions:; - Perindopril 4 mg (n = 49); - Candesartan 16 mg (n = 47); Dose titration and co-interventions: No titration; no co-interventions allowed Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: NR; - Assessors of outcomes: Yes; Was allocation concealment adequate?: Yes Baseline/run-in period: 4-wk placebo run-in Duration of treatment: 12 mo Duration of post-treatment followup: Patients followed for an additional month at the end of the trial after discontinuation of study meds | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 96; - Began treatment: 96; - Completed treatment: NR; - Withdrawals/losses to followup: NR; Age: Mean (SD): 54 median: NR Range: NR Sex (n [%]): Female: 49 (51%) Male: 47 (49%) Race/ethnicity (n [%]): NR, but presumably 100% Caucasian Baseline blood pressure: Trough seated BP measured 3 times at 1-min intervals after patient rested 10 min using a standard mercury sphygmomanometer (Erkameter 3000); average of 3 readings used | | | | | 1) Blood pressure: Mean change (± SD) in BP from baseline to 12 mo: | | | | | | General comments:; - Probably underpowered study; Quality assessment: Overall rating: Good Applicability:; - Very early diabetes with mild hypertension; - Patients in academic medical center in Italy; - Probably underpowered to detect true differences between the groups
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | | | | | | | | [underlined: Perindopril] | | [underlined: Candesartan]
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | | | | | | SBP | | -13 ± 4.5 | | -12 ± 4.1
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | | | | | | DBP | | -11 ± 3.6^*^ | | -8 ± 2.9
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | | | | | | ^*^p < 0.05, perindopril vs. candesartan; no other between-group comparisons statistically significant 1-mo, 6-mo, 1-mo posttreatment followup data also reported 2) Rate of use of a single antihypertensive agent for BP control: NA (no additional agents allowed) 3) Mortality: NR 4) Morbidity: NR 5) Safety: Any AE: Perindopril: 5/49 (10%) Candesartan: 3/47 (6%) No serious AEs. No withdrawals due to AEs. 6) Specific adverse events: Perindopril (n = 49): 2 (4%) cough, 4 (8%) abnormal taste, 1 (2%) epigastric discomfort Candesartan (n = 47): 1 (2%) headache, 2 (4%) dizziness, 1 (2%) nausea 7) Persistence/adherence: NR 8) Lipid levels: Values are mean ± SD:
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | | [underlined: Perindopril] | | [underlined: Candesarta] | | | | [underlined: Perindopri] | | [underlined: Candesartan]
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | SBP | 147 ± 6 | | 148 ± 6 | | LDL baseline | | 120 ± 18 | | 125 ± 15
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | DBP | 94 ± 4 | | 93 ± 5 | | LDL change 12 mo | | -14 ± 7.4^*^ | | -4 ± 1.8
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | Concurrent medications (n [%]): Glibenclamide: 43% Glipizide: 30% Gliclazide: 28% Comorbidities (n [%]): NR Recruitment setting: Department of Internal Medicine and Therapeutics at a single university hospital Inclusion criteria:; - Type 2 diabetes diagnosed < 6 mo before; - Mild hypertension (DBP 90-105 without meds); - Non-smokers; - Adequate glycemic control (HbA1c < 7.5%) with diet or oral hypoglycemic drugs; - Not on hypocholesterolemic drugs; - No retinopathy, neuropathy, or nephropathy; Exclusion criteria:; - Secondary hypertension; - Malignant hypertension; - Unstable angina; - MI within 6 months; - Liver disease; - Renal disease; - Contraindication to ACEI or ARB; - Already receiving ACEI or ARB | | | | | HDL baseline | | 43 ± 4 | | 40 ± 5
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | | | | | | HDL change 12 mo | | -2 ± 0.5 | | +2 ± 0.4
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | | | | | | TG baseline | | 160 ± 18 | | 149 ± 10
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | | | | | | TG change 12 mo | | -22 ± 11.6 | | +2 ± 0.8
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | | | | | | ^*^p < 0.05, perindopril vs. candesartan 6-mo and 1-mo posttreatment followup data also reported 9) Progression to type 2 diabetes: All already have type 2 diabetes 10) Markers of carbohydrate metabolism/diabetes control: Values are mean ± SD:
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | | | | | | | | [underlined: Perindopril] | | [underlined: Candesartan]
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | | | | | | HbA1c baseline | | 6.4 ± 0.9 | | 6.5 ± 1.1
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | | | | | | HbA1c change 12 mo | | -0.2 ± 0.1 | | -0.2 ± 0.1
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | | | | | | Fasting glucose baseline | | 155 ± 15 | | 160 ± 13
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | | | | | | Fasting glucose 1 yr | | -15 ± 4^*^ | | -8 ± 2
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | | | | | | ^*^p < 0.05, perindopril vs. candesartan 6-mo and 1-mo posttreatment followup data also reported 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: Values are mean ± SD:
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | | | | | | | | [underlined: Perindopril] | | [underlined: Candesartan]
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | | | | | | AER/24 hr baseline | | 17 (10) | | 18 (11)
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | | | | | | AER/24 hr change 12 mo | | -8 ± 3.6 | | -8 ± 4.1
Derosa, Cicero, Ciccarelli, et al., 2003 #1574 | | | | | | | 6-mo and 1-mo posttreatment followup data also reported

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Deyneli, Yavus, Velioglu, et al., 2006 #1431 | Geographical location: Istanbul, Turkey Study dates: NR Funding source: Supported by a grant from the Turkish Diabetes Foundation, Istanbul, Turkey Interventions: 6-week titration phase of either:; - Enalapril 5-20 mg/day (n = 12); - Losartan 50-100 mg/day (n = 12); targeting BP < 130/80 mm Hg Followed by 24-week maintenance phase Were additional antihypertension medications allowed: NR Study design: RCT, parallel-group Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: No; Was allocation concealment adequate?: Yes Baseline/run-in period: NA Duration of treatment: 6 months (6 weeks titration and 24 weeks maintenance) Duration of post-treatment followup: NR | Number of patients: N = 24; - Screened for inclusion: NR; - Eligible for inclusion: 28; - Randomized: 26; - Began treatment: 26; - Completed treatment: 24; - Withdrawals/losses to followup:1 enalapril (cough/dizziness) 1 losartan (non-compliant); Age: Mean (SD): 52.4 ± 6.0 Sex (n [%]): Female: 18 (75%) Male: 6 (25%) Race/ethnicity (n [%]): NR Baseline blood pressure: 3 seated recordings after 10 min rest: Enalapril: 144.1/89.5 mmHg (18.8/4.5) Losartan: 142.5/90.0 mmHg (18.6/6.7) Concurrent non-hypertension medications (n [%]): NR 22/24 on oral antidiabetic meds and 2/24 on insulin Comorbidities (n [%]): All patients had diabetes Recruitment setting: University endocrine and internal medicine clinics Inclusion criteria: Male and female patients attending Marmara University Hospital Endocrine and Internal Medicine outpatient clinics with Type 2 DM diagnosed after the age of 30, with mild-to-moderate essential HTN and microalbuminuria. All patients were hypertensive for at least 6 months according to hospital records and none were on antihypertensive treatment Exclusion criteria:; - Secondary HTN; - History of malignant HTN, MI, cerebrovascular disease, heart failure, treatment with antiaggregants, steroids, or other drugs that might effect BP; - Serum creatinine > 200 μmol/L; - Urinary tract infection and other systemic disorders | | | | | 1) Blood pressure: Post-treatment seated BP: Enalapril: 125.0/76.2 mmHg (15.6/7.1) Losartan: 122.5/75.4 mmHg (18.3/4.5) No significant between-group difference 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: See specific adverse events 6) Specific adverse events: 1 patient in enalapril had cough/dizziness. No reported AEs for losartan 7) Persistence/adherence: 1 pt in losartan withdrawn for non-compliance 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: Baseline GFR (creatinine clearance mL/min): Enalapril: 102.6 ± 22 Losartan: 115.9 ± 23 6 months Enalapril: 114.5 ± 30 Losartan: 111.6 ± 28 Statistical testing not reported. 13) Proteinuria: Urine albumin excretion (mg/day): Enalapril: 83.5 ± 51 at baseline 17.5 ± 7.4 at 6months Losartan: 80.1 ± 52 at baseline 19.3 ± 8.4 at 6months No significant between-group difference | | | | | | General comments: Primary outcomes are biochemical urine markers Quality assessment: Overall rating: Fair Comments: None Applicability: Not clear if other antihypertensive meds allowed during treatment phase

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Duprez, Munger, Botha, et al., 2010 (Epub 2009 Dec 24) #2112 AGELESS trial | Geographical location: 100 centers in the US Study dates: NR Funding source: Funded by Novartis Pharma AG, Basel, Switzerland. Novartis was represented on the trial steering committee in the study design, analysis, and interpretation of data. The sponsor provided study drug preparations. Editorial assistance was provided by Complete Healthcare Communications Inc. (Chadds Ford, PA, USA) and supported by Novartis Pharmaceuticals Corporation. Interventions:; - Aliskiren 150 mg/d, with increase to 300 mg/d at 4 or 8 weeks if sitting SBP ≥ 140 (n = 457); - Ramipril 5 mg/d, with increase to 10 mg/d at 4 or 8 weeks if sitting SBP ≥ 140 (n = 444); Were additional anti-hypertension medications allowed: Yes If Yes to above, was this done: Per protocol. HCTZ 12.5 mg/d added in either study arm at or after 12 weeks if sitting SBP ≥ 140. HCTZ increased to 25 mg/d at or after 16 weeks if sitting SBP ≥ 140. Amlodipine 5 mg/d added at or after 22 weeks if needed, and increased to 10 mg/d at 28 weeks if needed. Study design: RCT, parallel-group, double-blind, active-controlled, optional-titration Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: Yes; Was allocation concealment adequate?: Yes Baseline/run-in period: 1 to 2 weeks of discontinuation of anti-hypertensive medications prior to randomization Duration of treatment: 36 weeks Duration of post-treatment followup: None. Last assessment after 36 weeks of treatment. | Number of patients: N = 901; - Screened for inclusion: NR; - Eligible for inclusion: 1325; - Randomized: 901; - Began treatment: NR; - Completed treatment: 680 (75%); - Withdrawals/losses to followup: 221 (25%); Age: Mean (SD): All 72.1 ± 5.6 Aliskiren 72.0 ± 5.6 Ramipril 72.2 ± 5.6 Range: ≥ 65 (32.5% were ≥ 75) Sex (n [%]): Female: 472 (52.4%) Male: 429 (47.6%) Race/ethnicity (n [%]): White 767 (85.1%) Black 72 (8.0%) Asian/other 62 (6.9%) Baseline blood pressure: Sitting and standing BP 24 ± 3 h after dose, with standard mercury sphygmomanometer and appropriate cuff size at baseline and weeks 2, 4, 8, 12, 16, 22, 28, and 36. Sitting BP was measured three times after the patient had been sitting for 5 min, with back supported and both feet placed on the floor. Mean sitting SBP, mm Hg ± SD (range):; - Aliskiren: 156.5 ± 10.9 (137-190); - Ramipril: 156.6 ± 10.6 (140-181); Mean sitting DBP, mm Hg ± SD (range):; - Aliskiren: 85.5 ± 9.5 (51-109); - Ramipril: 78.4 ± 19.0 (60-107); Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): Diabetes: All: 20.6%; - Aliskiren: 99 (21.7); - Ramipril: 87 (19.6); Obesity: All: 40.2%; - Aliskiren: 183 (40.0); - Ramipril: 179 (40.3); Recruitment setting: Patients with essential hypertension recruited from 100 center in the US Per protocol, patients with SBP ≥ 180 or DBP ≥ 110 at any time, including run-in period, were withdrawn from study and appropriate therapy was instituted. Inclusion criteria: Men and women, age ≥ 65, with essential HTN (mean sitting SBP ≥ 140 to ≤ 180 mmHg and mean sitting DBP < 110mmHg) Exclusion criteria:; - History of severe cardiovascular or cerebrovascular disease or other life-threatening medical conditions; - Serum sodium or potassium < lower limit of normal or if serum potassium was ≥ 5.5 mEql^-1^; - Evidence of severe renal impairment with an estimated GFR < 30 mL/min per 1.73m^2^ as measured by the Modification of Diet in Renal Diseases formula; - Heavy proteinuria (urinary albumin to creatinine ratio > 3500 mgg^-1^) or evidence of the nephritic syndrome | | | | | 1) Blood pressure: Primary endpoint: change in SBP from baseline to week 12. [underlined: Mean sitting SBP, mm Hg ± SD] At week 12:; - Aliskiren:; Mean sitting SBP: 142.9 ± 18.0; Change: -14 ± 0.8; - Ramipril:; Mean sitting SBP: 145.3 ± 16.1; Change: -11.6 ± 0.8; - Change between treatments: -2.3 mm Hg (95% CI, -4.3 to -0.3); Conclusion: “Aliskiren monotherapy showed statistically non-inferior (p < 0.001) and statistically superior (p = 0.02) reduction in mean sitting SBP compared with ramipril therapy.” At week 22:; - Aliskiren: 137.0 ± 17.8; Change: -19.6 ± 0.8; - Ramipril: 139.6 ± 16.8; Change: -17.3 ± 0.8; - Change between treatments: -2.4 mm Hg (95% CI, -4.5 to -0.3; p = 0.03); At week 36:; - Aliskiren: 136.5 ± 17.3; Change: -20 ± 0.8; - Ramipril: 138.5 ± 16.9; Change: -18.1 ± 0.8; - Change between treatments: -1.9 mm Hg (95% CI, -4.0 to 0.2; p = 0.07); [underlined: Mean sitting DBP] At week 12:; - Aliskiren: 80.7 ± 10.7; Change: -5.1 ± 0.4; - Ramipril: 82.5 ± 9.6; Change: -3.6 ± 0.4; - Change between treatments: -1.5 mm Hg (95% CI, -2.6 to -0.5; p < 0.01); At week 22; - Aliskiren: 77.8 ± 10.4; Change: -8.2 ± 0.4; - Ramipril: 78.9 ± 10.3; Change: -7.3 ± 0.4; - Change between treatments: -0.8 mm Hg (95% CI, -2.0 to 0.3; p = 0.14); At week 36:; - Aliskiren: 77.6 ± 9.9; Change: -8.2 ± 0.5; - Ramipril: 79.1 ± 9.8; Change: -7.0 ± 0.4; - Change between treatments: -1.2 mm Hg (95% CI, -2.3 to -0.1; p = 0.03); At week 12, a greater percentage of aliskiren patients (42%) achieved BP control than ramipril patients (33%). BP changes were similar for aliskiren and ramipril in the subgroup of patients with Stage 2 HTN. BP changes appeared similar for age < 75 patients vs. ≥ 75 patients in aliskiren and ramipril groups (p values not reported). BP changes appeared less for black patients vs. white patients for aliskiren, but greater for black patients vs. whites for ramipril (p values not reported). 2) Rate of use of a single antihypertensive agent for BP control: Aliskiren: 42% Ramipril: 29% (statistical significance not reported) “A significantly greater percentage of patients receiving ramipril than aliskiren required additional HCTZ (56 vs. 46%; p < 0.01).” “Similarly, a greater percentage of patients receiving ramipril-based (16%) vs. aliskiren-based (12%) therapies required add-on therapy with both HCTZ and amlodipine by week 36 (p = 0.048).” 3) Mortality: None 4) Morbidity: NR 5) Safety: Any AE: Aliskiren: 328/452 (72.6%) Ramipril: 336/444 (75.7%) Serious AEs: Aliskiren: 35/452 (7.7%) Ramipril: 27/444 (6.1%) 6) Specific adverse events: The statistically significant differences were: | | | | | | General comments:; - Well-designed and well-reported study; - Industry sponsor was involved in data analysis, interpretation, and authorship; - Last observation carried forward was used to impute missing values in patients who discontinued before week 12; Quality assessment: Overall rating: Good Applicability: Good applicability. Good study design, appropriately powered, good blinding, and good reporting of methods and results. Insufficient data reported for recruitment and screening to know whether the sample population is representative of the larger population of patients with essential HTN in the U.S.
Duprez, Munger, Botha, et al., 2010 (Epub 2009 Dec 24) #2112 AGELESS trial | | | | | | | | | | [underlined: Aliskiren] | [underlined: Ramipril] | [underlined: p value]
Duprez, Munger, Botha, et al., 2010 (Epub 2009 Dec 24) #2112 AGELESS trial | | | | | | | D/C due to AEs | | | 32 (7.1) | 51 (11.5) | 0.023
Duprez, Munger, Botha, et al., 2010 (Epub 2009 Dec 24) #2112 AGELESS trial | | | | | | | Cough | | | 19 (4.2) | 59 (13.3) | < 0.0001
Duprez, Munger, Botha, et al., 2010 (Epub 2009 Dec 24) #2112 AGELESS trial | | | | | | | 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: eGFR change from baseline to week 36 (mL/min per 1.73 m^2^):; - Aliskiren: -3.20 ± 11.22; - Ramipril: -3.94 ± 12.32; Number (%) or patients exceeding pre-specified thresholds at any time post-baseline in creatinine and BUN: [underlined: Creatinine (> 176.8 micromol/L):]; - Aliskiren: 2 (0.5); - Ramipril: 1 (0.2); [underlined: BUN (> 14.28 mmol/L):]; - Aliskiren: 5 (1.1); - Ramipril: 4 (0.9); 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Eguchi, Kario, and Shimada, 2003 #1575 | Geographical location: Tochigi, Japan Study dates: NR Funding source: NR Interventions:; - Candesartan (4-12 mg) (n = 37); - Lisinopril (5-20 mg) (n = 36); Dose titration/co-interventions: Initially, all patients treated with candesartan (4-8 mg) or lisinopril (5-10 mg) (choice of dose not explained). Dosage of candesartan was then increased by 4 mg and dosage of lisinopril by 5-10 mg for 4 wk up to the maximum. If response not satisfactory (BP systolic < 140 and BP diastolic < 90) at 4-8 wk, then trichlormethazide 1-2 mg added At 12 wk, patients crossed over to the alternative drug as monotherapy, with dose titration and addition of diuretic repeated as above. Study design: RCT, crossover Blinding:; - Patients: NR; - Providers: NR; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: 1-week “washout” after randomization Washout period(s): No washout between study periods Duration of treatment: 2 × 12-week treatment periods Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 73; - Began treatment: 73; - Completed treatment: NR; - Withdrawals/losses to follow-up: NR; all 12 patients who experienced AEs were “excluded from the study”; - Population analyzed = 61; Age: Mean (SD): 69.3 ± 7.4 Median: NR Range: NR Sex (n [%]): Female: 57% Male: 43% Race/ethnicity (n [%]): NR Baseline blood pressure: Seated trough BP measured after patient seated for 5 min rest using a standard mercury sphygmomano-meter Mean baseline values for analyzed population (n = 61): DBP: 163 ± 17 SBP: 85 ± 11 Concurrent medications (n [%]): Comorbidities (n [%]): Diabetes 48% Smoker 23% Recruitment setting: Clinic office Inclusion criteria:; - Ambulatory, asymptomatic older patients with > 3 visits in a 14- to 28-day period with mean SBP > 150 mm Hg or mean DBP > 90 on > 2 occasions; Exclusion criteria:; - Serum creatinine > 2.5 mg/dL; - Major stroke, congestive heat failure, malignancy or other severe concomitant disease; - BP > 180/110 mm Hg on medication; - Note: Patients with MI with preserved LV contractility and those with “minor” stroke were not excluded | | | | | 1) Blood pressure: Mean seated trough BP at 12 wk: | | | | | | General comments:; - Meds taken before randomization (no clear run-in period described):; ACEI 41%; ARB 6.6%; Diuretics 16%; Calcium antagonist 64%; None 6.6%; Quality assessment: Overall rating: Poor Comments:; - Protocol not clearly defined, blinding not reported, no washout after period 1 of crossover, imbalance in treatment groups (apparently due to more patients discontinuing lisinopril and not continuing to period 2); - Of the 61 patients analyzed, 35 received candesartan first and 26 lisinopril first; - Patients with AEs (n = 12) excluded from efficacy analysis; Applicability:; - Apparently limited to Japanese patients in a single clinic
Eguchi, Kario, and Shimada, 2003 #1575 | | | | | | | | | Candesartan (n = 61) | | Lisinopril (n = 61)
Eguchi, Kario, and Shimada, 2003 #1575
Eguchi, Kario, and Shimada, 2003 #1575 | | | | | | | SBP | | 148 ± 16 | | 144 ± 18
Eguchi, Kario, and Shimada, 2003 #1575 | | | | | | | DBP | | 79 ± 11 | | 77 ± 9.8
Eguchi, Kario, and Shimada, 2003 #1575 | | | | | | | No significant difference between groups (p-values NR) Other outcomes reported: 24-hr ABPM outcomes 2) Rate of use of a single antihypertensive agent for BP control: Trichlormethazide added per protocol: Candesartan: 79% Lisinopril: 80% p = NS 3) Mortality: NR 4) Morbidity: NR 5) Safety: Patients with AEs requiring their “exclusion” from analysis: Candesartan: 2 patients (2.7%; 1 dim vision and 1 facial edema) Lisinopril: 10 patients (13.7%; 9 cough, 2 fatigue) (numbers given here as reported) 6) Specific adverse events: NR except AEs leading to withdrawal (see immediately above) 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | Geographical location: North America, Europe, and South Africa Study dates: NR Funding source: SmithKline Beecham Pharma (Collegeville, PA; since merged with GlaxoSmithKline, now GSK) Interventions:; - Enalapril 5 mg qd, with titration up to 20 mg qd (n = 264); - Eprosartan 200 mg bid, with titration up to 300 mg bid (n = 264); Both groups: HCTZ 12.5-25 mg qd added at 12 wk if DBP ≥ 90) Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes (titration/maint); - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: 3- to 5-wk single-blind placebo run-in Duration of treatment: 26 wk: 18-wk titration period + 8-wk maintenance period Duration of post-treatment followup: None | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 528; - Began treatment: NR; - Completed treatment: 447; - Withdrawals/losses to followup: NR (≥ 16); Age: Mean (± SEM): 55.6 ± 0.7 Median: NR Range: 23-84 Sex (n [%]): Female: 56.5% Male: 43.5% Race/ethnicity (n [%]): Caucasian 456 (86%) Black 40 (8%) Asian 6 (1%) Other 26 (5%) Baseline blood pressure (± SEM); Sitting BP measured in triplicate “according to standard techniques” | | | | | 1) Blood pressure: Mean post-treatment BP values NR [underlined: Overall study population] Mean change in BP from baseline (at 26 wk): | | | | | | General comments:; - An analysis comparing the subgroups < 65 years and ≥ 65 years of age found that the elderly subpopulation “mirrored the response of the study as a whole”; - An analysis of a subgroup of 40 black patients found that the black subpopulation “mirrored the response of the study as a whole”; Quality assessment: Overall rating: Fair Comments:; - Method of BP ascertainment not described; - Uncertainty about number of withdrawals (enumerated those w/d for serious AE and cough; but not for any other causes, if any); - One report described 529 patients instead of 528; other minor discrepancies across reports; Applicability:; - No list of participating centers (described as multinational); - Poor description of subjects' comorbidities, although exclusion criteria suggest a comparatively healthy group
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | | | [underlined: Enalapril] | | [underlined: Eprosartan]
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Sit SBP | | -14.7 | | -15.5 mm Hg
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Sit DBP | | -11.9 | | -12.9 mm Hg
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Response rates (DBP < 90 or DBP < 100 and a reduction of ≥ 10 mm Hg from baseline):
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | | | [underlined: Enalapril] | | [underlined: Eprosartan]
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | 12 wk | | 62.6% 70 | | 3% (p < 0.05)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | 26 wk | | 73.4% | | 81.7% (p < 0.02)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | [underlined: ≥ 65 years subgroup] Mean change in BP from baseline (at 26 wk):
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | | | [underlined: Enalapril] | | [underlined: Eprosartan]
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Sit SBP | | -15.3 ± 2.2 | | -18.9 ± 2.1 (NS)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Sit DBP | | -12.2 ± 1.1 | | -13.9 ± 1.1 (NS)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Response rates:
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | [underlined: Enalapril] | | [underlined: Eprosartan] | | | | [underlined: Enalapril] | | [underlined: Eprosartan]
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | SBP | 156.2 ± 0.9 | | 156.4 ± 0.9 | | 26 wk | | 48 (77.4%) | | 55 (87.3%) (NS
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | DBP | 101.2 ± 0.3 | | 100.7 ± 0.3 | | [underlined: Black patient subgroup] Mean change in BP from baseline (at 26 wk):
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | Baseline values also reported for ≥ 65 years subgroup and black subgroup Concurrent medications (n [%]): NR; concomitant use of medications know to affect BP prohibited Comorbidities (n [%]): Current smoker: Enalapril: 31 (12%) Eprosartan: 36 (14%) See also Exclusion criteria, below Recruitment setting: NR Inclusion criteria:; - Age ≥ 18 yr; - Essential HTN (sitting DBP 95-114 mm Hg); Exclusion criteria:; - Secondary forms of hypertension; - Advanced hypertensive retinopathy; - Sitting SBP > 200 mmHg; - MI or CVA < 90 days; - CHF or angina; - Advanced AV conduction defects, ventricular tachyarrhythmias, bradycardia; - Unstable DM; - Clinically significant renal or hepatic disease; - Other concurrent severe disease; - Emphysema, chronic bronchitis, asthma with cough, URI < 2 wks
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | | | [underlined: Enalapril] | | [underlined: Eprosartan]
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Sit SBP | | -10.5 ± 3.7 | | -18.8 ± 3.5 (NS)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Sit DBP | | -9.6 ± 2.4 | | -10.5 ± 1.9 (NS)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Response rates:
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | | | [underlined: Enalapril] | | [underlined: Eprosartan]
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | 12 wk | | 5 (26.3%) | | 11 (52.4%) (p < 0.05)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | 26 wk | | 8 (42.1%) | | 14 (66.7%) (p = 0.02)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | 2) Rate of use of a single antihypertensive agent for BP control: Eprosartan group: HCTZ added in 81 patients Enalapril group: HCTZ added in 81 patients 3) Mortality: One death in eprosartan group; judged to be unrelated 4) Morbidity: One MI in eprosartan group, judged to be unrelated to treatment. The between-group differences in changes in Psychological General Well Being (PGWB) scores were -2.48 (95% CI -4.63 to -0.32) for the study end point and -0.79 (-2.72 to 1.15) for monotherapy end point. At monotherapy end point there were no significant differences between treatments (data not presented). 5) Safety:
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | | | [underlined: Enalapril] | | [underlined: Eprosartan]
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Severe AE | | 32 (12.1%) | | 24 (9.1%)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Tx-related | | 16 (6.1%) | | 10 (3.8%)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Serious nonfatal | | 8 (3.0%) | | 4 (1.5%)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | ≥ 1 AE | | 213 (80.7%) | | 201 (76.1%)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | ≥ 65 years subgroup
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | All AE | | 48 (77.4%) | | 46 (73.0%)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | All Serious | | 7 (11.3%) | | 4 (6.3%)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Serious - w/d | | 1 | | 1
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Serious - no w/d | | 3 | | 0
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | 6) Specific adverse events:
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | | | [underlined: Enalapril] | | [underlined: Eprosartan]
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Definite cough | | 14 (5.4%) | | 4 (1.5%)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Cough (p = 0.01) | | 59 (22.3%) | | 34 (12.9%)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Pharyngitis | | 64 (24.2%) | | 44 (16.7%)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Headache | | 37 (14.0%) | | 39 (14.8%)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Rhinitis | | 43 (16.3%) | | 33 (12.5%)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | URI | | 43 (16.3%) | | 33 (12.5%)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Myalgia | | 16 (6.1%) | | 25 (9.5%)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Dyspnea | | 17 (6.4%) | | 14 (5.3%)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Dizziness | | 21 (8.0%) | | 13 (4.9%)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | Fatigue | | 18 (6.8%) | | 13 (4.9%)
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | ^*^definite cough – persistent, non-productive (dry) cough assoc. with tx and not due to URI as judged by investigator
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | 7) Persistence/adherence: NR 8) Lipid levels:
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | | | Eprosartan baseline end | | Enalapril baseline end
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | LDL-c | | 3.5±0.8 | 3.6±0.9 | 3.5±0.9 | 3.7±0.9
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | HDL-c | | 1.4±0.3 | 1.4±0.4 | 1.4±0.4 | 1.4±0.3
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | TG | | 1.6±1.0 | 1.6±1.1 | 1.6±1.0 | 1.7±1.1
Elliott, 1999 #1576 and Gavras and Gavras, 1999 #1583 and Levine, 1999 #1593 and Argenziano and Trimarco, 1999 #1557 and Breeze, Rake, Donoghue, et al., 2001 #1564 | | | | | | | 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: “Neither eprosartan nor enalapril significantly affected … blood glucose” at any time point. 11) LV mass/function: NR 12) Creatinine/GFR: “The degree and direction of … renal function tests were comparable in both treatment groups.” 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Erkens, Panneman, Klungel, et al., 2005 #1577 | Geographical location: 25 medium-sized cities in The Netherlands Study dates: Included patients received treatment between 1997 and 2001 Funding source: Novartis Pharma, B.V. (The Netherlands) Interventions: Diuretics (n = 458) Beta-blockers (n = 471) CCBs (n = 455) ACEIs (n = 412) ARBs (n = 447) Study design: Retrospective cohort study Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: No; Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: NR Duration of post-treatment followup: Patients followed for 15 mo after their index data | Number of patients:; - Screened for inclusion: 48,234; - Eligible for inclusion: 2243 (after random selection of 500 per group and post-selection exclusions); - Randomized: NA; - Began treatment: NA; - Completed treatment: NA; - Withdrawals/losses to followup: NA; Age: Mean (SD):NR Median: NR Range:; - 0-19: 1.6%; - 20-39: 11.5%; - 40-59: 42.6%; - 60-79: 37.0%; - ≥ 80: 7.4%; Sex (n [%]): Female: 1276 (56.9%) Male: 967 (43.1%) Race/ethnicity (n [%]): NR Baseline blood pressure: NR Concurrent medications (n [%]): Antidiabetic drugs: 11.3% Lipid-lowering drugs: 9.4% Antiasthmatic drugs: 14.2% Comorbidities (n [%]): Prior CV hospitalizations: 8.2% Recruitment setting:; - Data drawn from community-based database linking drug-dispensing records from pharmacies and hospital discharge records; - Patients receive first antihypertensive prescription from GP (85%), internist (5.8%), cardiologist (4.0), or other (5.2%); Inclusion criteria:; - From base cohort (n = 48,234), patients selected who:; 1. did not use antihypertensive drugs in the year before the index date;; 2. were registered in the database for ≥ 1 yr before and ≥ 15 mo after their first prescription for antihypertensive drugs; and; 3. received at least two prescriptions for antihypertensive drugs; - From this group, 500 per drug class randomly drawn for analysis; Exclusion criteria: Patients using fixed combination drugs | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: 1-yr persistence (defined as the % of patients who used a given drug for ≥ 270 days and had an additional drug dispensing in the 3 mo after the followup period): | | | | | | General comments:; - High-quality administrative data in a population-based sample; Quality assessment: Overall rating: Fair Comments:; - Non-random allocation to drugs; - No data on comparability of patients on ACEIs versus ARBs; - Funded by pharmaceutical company; Applicability:; - Specific ACEIs and ARBs not identified
Erkens, Panneman, Klungel, et al., 2005 #1577 | | | | | | | Diuretics: | | | 33.0%
Erkens, Panneman, Klungel, et al., 2005 #1577 | | | | | | | Beta-blockers: | | | 35.0%
Erkens, Panneman, Klungel, et al., 2005 #1577 | | | | | | | CCBs: | | | 34.7%
Erkens, Panneman, Klungel, et al., 2005 #1577 | | | | | | | ACEIs: | | | 59.7%
Erkens, Panneman, Klungel, et al., 2005 #1577 | | | | | | | ARBs: | | | 62.0%
Erkens, Panneman, Klungel, et al., 2005 #1577 | | | | | | | Persistence increased with male sex, increasing age, use of antidiabetic drugs, use of lipid-lowering drugs, and prior cardiovascular hospitalizations (all in univariable analyses) 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Fernandez-Campo, Grande, Diego, et al., 2009 #72 | Geographical location: Salamanca, Spain Study dates: July 2004–Jan 2008 Funding source: European Commission Research Directorates General [grant number ERG-Mobility-11 #508782]; the Instituto de Salud Carlos III (Ministerio de Sanidad y Consumo) [grant numbers CP01/00094, P1041817]; the Junta de Castilla y León [grant numbers SA001/C05, SA029/A05]; and the Fundación de Investigación Médica Mutua Madrileña Interventions:; - 13 patients with hypertension without diabetes treated with ARBs (600 mg/day eprosartan [n = 9], 50 mg/day losartan [n = 2] or 80 mg/day valsartan [n = 2]);; - 19 patients with hypertension without diabetes treated with ACEI (either 20 mg/day enalapril [n = 12] or 2 mg/day trandolapril [n = 7]);; - 23 patients with hypertension and diabetes treated with ARBs (600 mg/day eprosartan [n = 2], 50–100 mg/day losartan [n = 2], 80–160 mg/day valsartan [n = 18] or 150 mg/day irbesartan [n = 1]);; - 9 patients with hypertension and diabetes treated with ACEI (20–40 mg/day enalapril [n = 4], 2 mg/day trandolapril [n = 3], 20 mg/day lisinopril [n = 1] or 10 mg/day imidapril [n = 1]).; Were additional anti-hypertension medications allowed: No Study design: Other – non-randomized clinical trial Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: No; Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: 3 months Duration of post-treatment followup: NA | Number of patients: N = 81; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: NA; - Began treatment: 81; - Completed treatment: NR; - Withdrawals/losses to followup: NR; Age: Mean (SD): 62.15 ±4.41 Sex (n [%]): Female: 29 (35.8%) Male: 52 (64.2%) Race/ethnicity (n [%]): NR Baseline blood pressure: SAP (mmHg): Patients with hypertension ARBs 151 ± 5 ACEIs 165 ± 3 Patients with hypertension and diabetes ARBs 174 ± 5 ACEIs 178 ± 7 DAP (mmHg) Patients with hypertension ARBs 93 ± 4 ACEIs 96 ± 2 Patients with hypertension and diabetes ARBs 93 ± 3 ACEIs 99 ± 5 MAP (mmHg) Patients with hypertension ARBs 112 ± 4 ACEIs 119 ± 2 Patients with hypertension and diabetes ARBs 120 ± 3 ACEIs 125 ± 5 Concurrent non-hypertension medications (n [%]): None Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria: Newly diagnosed essential arterial HTN (BP 140/90 mmHg, or 130/80 mmHg in pts with DM) w/o or with diabetes (blood glucose > 125 mg/dl), mainly type 2 DM Exclusion criteria:; - Previous antihypertensive treatment; - Serious pathologies (other than HTN and DM); - Renal or hepatic failure Cardiac congestive insufficiency; - Treatment with corticosteroids, non-steroid anti-inflammatory drugs and other potential HTN-inducing drugs; - Heavy smoking; - Alcoholism | | | | | 1) Blood pressure: 3 months (means ± +/- SEM) [note not standard deviation] SAP (mmHg) Patients with hypertension ARBs 126 ± 5 ACEi 128 ± 2 Patients with hypertension and diabetes ARBs 156 ± 7 ACEi 157 ± 11 DAP (mmHg) Patients with hypertension ARBs 80 ± 3 ACEi 78 ± 2 Patients with hypertension and diabetes ARBs 85 ± 3 ACEi 89 ± 4 MAP (mmHg) Patients with hypertension ARBs 95 ± 3 ACEi 95 ± 2 Patients with hypertension and diabetes ARBs 109 ± 4 ACEi 111 ± 6 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | | General comments: None Quality assessment: Overall rating: Poor Comments: No discussion of how patients were found, or how randomized to treatment Applicability:; - Patients were not randomized; - Does not provide information about adverse events

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Fogari, Derosa, Ferrari, et al., 2008 #1221 | Geographical location: Pavia, Italy Study dates: Sep 1, 2004 – Aug 30, 2007 Funding source: NR Interventions:; - Ramipril (5 mg, titrated to 7.5 mg titrated to 10 mg, 124 patients); - Valsartan (160 mg titrated to 240 mg titrated to 320mg, 122 patients); Titrated after 4 weeks and 8 weeks of treatment to achieve a target BP of < 140/90 mmHg Study also included amlodipine group (n = 123) Were additional anti-hypertension medications allowed: NR (possibly allowed as long as not “AT1R blockers, ACEIs, or antiarrythmic agents”) If Yes to above, was this done: NA (certainly not per protocol) Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: Yes; Was allocation concealment adequate?: NR Baseline/run-in period: 2-week placebo period Duration of treatment: 1 year Duration of post-treatment followup: NA | Number of patients: N = 246; - Screened for inclusion: 450; - Eligible for inclusion: 369; - Randomized: 369; - Began treatment: 246 (note additional 123 randomized to amlodipine but results not relevant here); - Completed treatment: 192; - Withdrawals/losses to followup: 54; Age: Mean (SD): 65 ± 7.5 Sex (n [%]): Female: 132 (53.7%) Male: 114 (46.3%) Race/ethnicity (n [%]): NR Baseline blood pressure: BP measurements were obtained from each patient in the seated position using a standard mercury sphygmomanometer (Korotkoff I and V). Measurements were taken in the morning before daily drug intake (i.e., 24 h after dosing) and after the subject had rested 10 min in a quiet room. Three successive BP readings were taken at 1-min intervals and averaged. SBP (mm Hg): Ramipril 152 ± 7 Valsartan 153 ± 7 DBP (mm Hg): Ramipril 95 ± 2 Valsartan 95 ± 3 Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): All patients had history of recent AF episode | | | | | 1) Blood pressure: There were substantial reductions in SBP and DBP values in the two treatment groups. At the end of follow-up, SBP was reduced by 15.7 mm Hg (P < 0.001 vs. baseline) in the valsartan group, and by 15.8 mm Hg in the ramipril group (P < 0.001 vs. baseline), with no significant difference between treatments. Corresponding changes for DBP were 12.1, 12.2 mm Hg (P < 0.001 vs. baseline), respectively, again without any significant difference between treatments. 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: See AE findings below, as well as safety/specific adverse events 5) Safety: Total AEs requiring the discontinuation of treatment occurred in 5 patients in the ramipril group, and 1 patient in the valsartan group. In the ramipril group, 1 patient had an atrial flutter and underwent radiofrequency ablation, and 4 patients discontinued because of an intolerable and unproductive cough. In the valsartan group, 1 patient discontinued because of hypotension. 6) Specific adverse events: See immediately above 7) Persistence/adherence: Ramipril: Discontinued AE n = 5 Uncontrolled BP n = 22 Other n = 4 Valsartan: Discontinued AE n = 1 Uncontrolled BP n = 20 Other n = 2 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR 14) Atrial fibrillation: Intention-to-treat analysis Recurrence of atrial fibrillation at 12 weeks after randomization: Ramipril 11 Valsartan 5 Recurrences of atrial fibrillation at 1 year after randomization Ramipril 26 Valsartan 16^*^ Days to recurrence, median ± SD (range) Ramipril 126 ± 79 (44–344) Valsartan 160 ± 94 (69–350) ^*^P < 0.05 vs. ramipril. At the 12-week follow-up visit (end of titration period), 33 patients had a recurrence of atrial fibrillation: by intention-to-treat analysis, the occurrence rate was significantly lower in the valsartan group (5 patients) than in the amlodipine group (17 patients). Kaplan–Meier analysis demonstrated a 12-week probability of 95% for maintaining sinus rhythm in patients who received valsartan compared with 91% in patients who received ramipril and 85% in patients who received amlodipine (P = 0.02). At the end of the follow-up (median 258 days [range 29–360]), 46 (47.4%) patients undergoing treatment with amlodipine had a recurrence of atrial fibrillation, as did 26 (27.9%) patients undergoing treatment with ramipril (P < 0.01 vs. amlodipine) and 16 (16.1%) patients undergoing treatment with valsartan (P < 0.01 vs. amlodipine and P < 0.05 vs. ramipril). Figure 2 in the manuscript shows the Kaplan–Meyer AF recurrence-free survival analysis, which demonstrated a significant reduction in AF recurrence in the valsartan group (P = 0.005 log-rank test) as well as in the ramipril group (P = 0.021 log-rank test) when compared to the amlodipine group, but also in the valsartan group (P = 0.045 log-rank test) when compared to the ramipril group. | | | | | | General comments: Patients who did not achieve BP control were excluded from analyses Quality assessment: Overall rating: Good Applicability: No limitations noted
Fogari, Derosa, Ferrari, et al., 2008 #1221 | | | [underlined: Ramipril] | | [underlined: Valsartan] | | | | | | | | General comments: Patients who did not achieve BP control were excluded from analyses Quality assessment: Overall rating: Good Applicability: No limitations noted
Fogari, Derosa, Ferrari, et al., 2008 #1221 | | LVH | 14(11.3) | | 16(13.1) | | | | | | | | General comments: Patients who did not achieve BP control were excluded from analyses Quality assessment: Overall rating: Good Applicability: No limitations noted
Fogari, Derosa, Ferrari, et al., 2008 #1221 | | Recruitment setting: Hypertension referral center Inclusion criteria: Outpatients of either sex, with mild essential HTN, in sinus rhythm but with at least two ECG-documented episodes of symptomatic AF in the previous 6 months, and without any antiarrythmic treatment Exclusion criteria:; - Treatment with AT1R blockers, ACEIs, or antiarrythmic agents, cardioversion within the last 8 weeks; - Secondary HTN; - MI or stroke in the preceding 6 months; - CHF, coronary heart disease, valvular disease, DM, a left atrium size > 45 mm, need to continue the use of digitalis, or cardiac surgery during the previous 6 months; - Significant thyroid, pulmonary renal of hepatic disease; - Pregnancy or fertile female; - Known hypersensitivity or contraindications to study medications | | | | | | | | | | | General comments: Patients who did not achieve BP control were excluded from analyses Quality assessment: Overall rating: Good Applicability: No limitations noted

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | Geographical location: Pavia, Italy Study dates: NR Funding source: NR Interventions:; - Perindopril 4 mg daily (n = 42); - Losartan 50 mg daily (n = 43); No dose titration; no co-interventions specified Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: 4-wk placebo run-in Duration of treatment: 12 wk Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 85; - Began treatment: 85; - Completed treatment: 82; - Withdrawals/losses to followup: 3 (2 due to AEs, 1 failure to appear at visit); Age: Mean (SD): 58.4 (8.0) Median: NR Range: 46-64 Sex (n [%]): Female: 40 (47%) Male: 45 (53%) Race/ethnicity (n [%]): NR Baseline blood pressure: Trough seated BP assessed using a standard mercury sphygmanometer; 3 readings taken at 1-min intervals after patient rested 10 min; average of 3 readings used | | | | | 1) Blood pressure: Mean trough seated BP at 12 wk: | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments:; - Numbers screened and eligible NR; - AEs not well reported; - Details of dose titration and concomitant med use (if any) not given; Applicability:; - 100% of study population also has type 2 diabetes; - Racial diversity not described (? 100% Caucasian); - Recruitment setting(s) not described; - 44 patients never treated before for hypertension
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | | | [underlined: Perindopril] | | [underlined: Losartan]
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | SBP | | 146 ± 10 | | 147 ± 11
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | DBP | | 87 ± 5 | | 88 ± 5
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | p = 0.001 for all pre-/post- comparisons p = NS for between-treatment comparisons Mean change in BP at 12 wk:
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | | | [underlined: Perindopril] | | [underlined: Losartan]
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | SBP | | -16 | | -15
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | DBP | | -15 | | -14
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | p < 0.001 for all pre-/post- comparisons p = NS for between-treatment comparisons 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: 2 withdrawals due to AEs – treatment group(s) not specified 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: Mean HDL (mg/dL):
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | [underlined: Perindopril] | | [underlined: Losartan] | | [underlined: Baseline] | | [underlined: 12 wk] | | [underlined: p-value]
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | SBP | 163.2 ± 12.9 | | 162.9 ± 12.6 | | Perindopril | | 44 ± 5 | | 46 ± 6 NS
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | DBP | 102.8 ± 6.1 | | 102.7 ± 5.9 | | Losartan | | 44 ± 5 | | 46 ± 6 NS
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): 100% type 2 diabetes Recruitment setting: NR Inclusion criteria:; - Adult men and women; - Documented mild-to-moderate essential HTN (DBP 90-110); - Concomitant type 2 diabetes in stable metabolic control with diet and oral hypoglycemic agents; Exclusion criteria:; - Secondary HTN; - Previous or active ischemic heart disease; - Serum creatinine > 1.5 mg/dL; - Chronic liver disease; - Obesity (BMI >28); - Pregnancy
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | Mean total cholesterol (mg/dL):
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | [underlined: Baseline] | | [underlined: 12 wk] | | [underlined: p-value]
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | Perindopril | | 197 ± 23 | | 186 ± 19 NS
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | Losartan | | 191 ± 20 | | 188 ± 19 NS
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | Mean triglycerides (mg/dL):
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | [underlined: Baseline] | | [underlined: 12 wk] | | [underlined: p-value]
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | Perindopril | | 142 ± 49 | | 127 ± 44 NS
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | Losartan | | 145 ± 50 | | 140 ± 48 NS
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: Mean FBG (mg/dL):
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | [underlined: Baseline] | | [underlined: 12 wk] | | [underlined: p-value]
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | Perindopril | | 112 ± 7.3 | | 107 ± 6.9 NS
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | Losartan | | 113 ± 7.5 | | 111 ± 7.0 NS
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | Mean HbA1c (%):
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | [underlined: Baseline] | | [underlined: 12 wk] | | [underlined: p-value]
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | Perindopril | | 7.2 ± 1.9 | | 7.1 ± 1.7 NS
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | Losartan | | 6.9 ± 2.0 | | 7.0 ± 1.8 NS
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | 11) LV mass/function: NR 12) Creatinine/GFR: Mean serum creatinine (mg/dL):
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | [underlined: Baseline] | | [underlined: 12 wk] | | [underlined: p-value]
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | Perindopril | | 1.1 ± 0.4 | | 1.1 ± 0.4 NS
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | Losartan | | 1.1 ± 0.5 | | 1.1 ± 0.4 NS
Fogari, Mugellini, Zoppi, et al., 2002 #1578 | | | | | | | 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Fogari, Mugellini, Zoppi, et al., 2004 #1579 | Geographical location: NR (authors based in Pavia, Italy) Study dates: NR Funding source: NR Interventions:; - Valsartan 160 mg (n = 75); - Enalapril 20 mg (n = 75); No dose titration; no co-interventions permitted Study design: RCT, parallel-group Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: Yes; Was allocation concealment adequate?: NR Baseline/run-in period: 2-wk run-in; previous anti-HTN treatment withdrawn Duration of treatment: 16 wk Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 150; - Began treatment: 150; - Completed treatment: 140; - Withdrawals/losses to followup: 6 (2 due to lack of compliance, 3 due to missed clinic visit, and 1 due to concomitant illness); Age: Mean (SD): 70.3 ± 5.7 Median: NR Range: NR Sex (n [%]): Female: 79/144 (54%) Male: 65/144 (46%) Race/ethnicity (n [%]): NR Baseline blood pressure: Trough seated BP measured using a standard mercury sphygmomano-meter after patient rested in sitting position for 5 min; mean of 3 measurement taken at 2-min intervals used | | | | | 1) Blood pressure: Trough seated BP at 16 wk: | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments:; - Not everyone blinded; - No titration for increase blood pressure; Applicability:; - Many comorbidities excluded in this elderly population and again comorbidities not presented; - No data on race/ethnicity of subjects
Fogari, Mugellini, Zoppi, et al., 2004 #1579 | | | | | | | | | | Valsartan [underlined: (n = 73)] | Enalapril [underlined: (n = 71)] | [underlined: P-value]
Fogari, Mugellini, Zoppi, et al., 2004 #1579 | | | | | | | SBP | | | 147.3 ± 7.3 | 150.2 ± 8.0 | < 0.01
Fogari, Mugellini, Zoppi, et al., 2004 #1579 | | | | | | | DBP | | | 87.1 ± 4.7 | 90.4 ± 5.0 | < 0.001
Fogari, Mugellini, Zoppi, et al., 2004 #1579 | | | [underlined: Valsartan] | | [underlined: Enalapril] | | BP normalized at 16 wk (DBP < 90 mm Hg): Valsartan: 60.2% Enalapril: 52.1% p = NS 2) Rate of use of a single antihypertensive agent for BP control: See immediately above on % of patients who normalized at 16 wk on monotherapy. 3) Mortality: NR 4) Morbidity: NR 5) Safety: Any AE: Valsartan: 5 (6.8%) Enalapril: 9 (12.6%) No serious AEs that were considered to be drug-related 6) Specific adverse events: Cough n = 4 enalapril and n = 1 valsartan HA V = 2 and E = 2 Nausea V = 1 E = 2 7) Persistence/adherence: “Patient compliance to both treatments was satisfactory” (no quantitative data reported) 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Fogari, Mugellini, Zoppi, et al., 2004 #1579 | | SBP | 165.9 ± 7.3 | | 165.8 ± 6.8
Fogari, Mugellini, Zoppi, et al., 2004 #1579 | | DBP | 100.8 ± 3.7 | | 100.9 ± 3.9
Fogari, Mugellini, Zoppi, et al., 2004 #1579 | | Concurrent medications (n [%]): NR; concomitant drugs with antihypertensive properties prohibited Comorbidities (n [%]): NR Recruitment setting: Outpatient clinics Inclusion criteria: Outpatients 61-80 years of age with mild-moderate hypertension (DBP ≥ 95 and ≤ 110) at end of 2-wk run-in Exclusion criteria:; - Secondary arterial hypertension, sitting systolic blood pressure > 200, malignant hypertension, K_W retinopathy III or IV, a hx of HTN encephalopathy; - CVA within 6 months, previous or current heart failure, MI within 6 months, angina, valvulopathy or relevant arrythmia; - Hepatic or renal dysfunction; - Clinical hypo or hyperthyroidism; - Known hypersensitivity to ACEI or ARB

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Fogari, Mugellini, Zoppi, et al., 2006 #283 | Geographical location: Pavia, Italy Study dates: NR Funding source: NR Interventions:; - Telmisartan 80 mg/HCTZ 12.5 mg (n = 80); - Lisinopril 20 mg/HCTZ 12.5 mg (n = 80); Were additional anti-hypertension medications allowed: No Study design: RCT, parallel-group {([prospective, open-label, blinded end point, parallel-group design [PROBE]) Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: Yes; Was allocation concealment adequate?: NR Baseline/run-in period: 2-weeks Duration of treatment: 24 weeks Duration of post-treatment followup: NA | Number of patients: N = 160; - Screened for inclusion: NR; - Eligible for inclusion: 160; - Randomized: 160; - Began treatment: 160; - Completed treatment: 147; - Withdrawals/losses to followup: 13; Age: Mean (SD): 67.6 ± 4.5 Range: 61 to 75 Sex (n [%]): Female: 84 (52.5%) Male: 76 (47.5%) Race/ethnicity (n [%]): NR Baseline blood pressure: Baseline readings for ambulatory blood pressure readings are listed in the results Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria: Sitting DBP ≥ 95 and < 110 mmHg and sitting SBP > 140 mmHg Exclusion criteria:; - Secondary HTN; - MI or cerebrovascular accident within the preceding 6 months; - Clinically significant valvular heart disease, heart failure, renal or hepatic insufficiency; - Known hypersensitivity to the drugs used in the study | | | | | 1) Blood pressure: Mean values of ambulatory BP (SBP ± SD/DBP ± SD) during treatment with telmisartan/HCTZ and lisinopril/HCTZ: [underlined: 24-hour ambulatory BP:] Baseline: Telmisartan/HCTZ: 151.5 ± 9.9 Lisinopril/HCTZ: 151.3 ± 10.2 12 weeks: Telmisartan/HCTZ: 132.1 ± 5.0 Lisinopril/HCTZ: 133.6 ± 5.5 24 weeks: Telmisartan/HCTZ: 129.3 ± 5.2^*^ Lisinopril/HCTZ: 131.7 ± 5.4 ^*^P < 0.05 vs. lisinopril/HCTZ [underlined: Daytime ambulatory BP:] Baseline: Telmisartan/HCTZ: 155.8 ± 9.9 Lisinopril/HCTZ: 155.5 ± 10.2 12 weeks: Telmisartan/HCTZ: 136.0 ± 5.0^*^ Lisinopril/HCTZ: 137.5 ± 5.5 24 weeks: Telmisartan/HCTZ: 133.1 ± 5.3^*^ Lisinopril/HCTZ: 135.4 ± 5.4 ^*^P < 0.05 vs. lisinopril/HCTZ [underlined: Nigh time ambulatory BP:] Baseline: Telmisartan/HCTZ: 138.7 ± 11.5 Lisinopril/HCTZ: 138.7 ± 11.6 12 weeks: Telmisartan/HCTZ: 120.4 ± 6.8 Lisinopril/HCTZ: 121.8 ± 7.4 24 weeks: Telmisartan/HCTZ: 117.4 ± 6.8^*^ Lisinopril/HCTZ: 119.8 ± 7.2 ^*^P < 0.05 vs. lisinopril/HCTZ 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: Six patients reported one or more AEs; two (2.6%) treated with telmisartan (one headache, one dizziness) and four (5.5%) treated with lisinopril (2 cough, 1 dizziness, 1 gastric discomfort) 6) Specific adverse events: See immediately above 7) Persistence/adherence: Based on pill counting, 94% of prescribed tablets were taken during telmisartan therapy and 92% during lisinopril, indicating good treatment compliance 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | | General comments: Study focuses on cognitive function in elderly hypertensive patients Quality assessment: Overall rating: Fair Comments: None Applicability:; - Not enough description of patient recruitment

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Fogari, Zoppi, Preti, et al., 2001 #1580 | Geographical location: Pavia, Italy Study dates: NR Funding source: NR Interventions:; - Trandolapril 2 mg daily (n = 45); - Losartan 50 mg daily (n = 44); Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: 4-wk placebo run-in period Duration of treatment: 12 wk Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 89; - Began treatment: 89; - Completed treatment: 89; - Withdrawals/losses to followup: NA; Age: Mean (SD): 55.5 (2) Median: NR Range: 51-60 Sex (n [%]): Female: 89 (100%) Male: 0 Race/ethnicity (n [%]): NR Baseline blood pressure: Seated trough BP measured using a standard mercury sphygmanometer; mean of 3 readings at 1-min intervals after 10 min rest | | | | | 1) Blood pressure: Mean trough seated BP at 12 wk: | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments:; - Numbers screened and eligible NR; - AEs not well reported; - Details of dose titration and concomitant med use (if any) not given; Applicability:; - 100% of study population post-menopausal women; - Racial diversity not described (? 100% Caucasian); - Recruitment setting(s) not described
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | | | [underlined: Trandolapril] | | [underlined: Losartan]
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | SBP | | 145.2 ± 10 | | 145.5 ± 11
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | DBP | | 88.1 ± 4 | | 88.6 ± 5
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | p < 0.01 for all pre-/post- comparisons p = NS for between-treatment comparisons Mean change in BP at 12 wk:
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | | | [underlined: Trandolapril] | | [underlined: Losartan]
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | SBP | | -17 | | -15
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | DBP | | -13 | | -12
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | p < 0.01 for all pre-/post- comparisons p = NS for between-treatment comparisons 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: Mean HDL (mg/dL):
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | [underlined: Trandolapril] | | [underlined: Losartan] | | | | [underlined: Baseline] | | [underlined: 12 wk] | [underlined: p-value]
Fogari, Zoppi, Preti, et al., 2001 #1580 | | SBP | 162.1 ± 12 | | 160.6 ± 12 | | Trandolapril | | 50 ± 15 | | 50 ± 16 | NS
Fogari, Zoppi, Preti, et al., 2001 #1580 | | DBP | 101.2 ± 5 | | 100.5 ± 5 | | Losartan | | 49 ± 16 | | 48 ± 17 | NS
Fogari, Zoppi, Preti, et al., 2001 #1580 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria:; - Mild-moderate essential HTN (DBP 90-110 mm Hg; - Postmenopausal women (defined by cessation of menses ≥ 1yr; confirmed by: (1) plasma FSH > 20 U/L; (2) FSH > LH levels; and (3) plasma 17-β-estradiol < 50 pmol/L); Exclusion criteria:; - Hormone replacement therapy < 6 mo; - Diabetes mellitus, obesity, smoking, MI, or stroke < 6 mo; - History of breast cancer or thromboembolic disease; - Major systemic diseases; - Any condition that would require use of concomitant medications | | | | | Mean total cholesterol (mg/dL):
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | | | [underlined: Baseline] | | [underlined: 12 wk] | [underlined: p-value]
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | Trandolapril | | 231 ± 31 | | 226 ± 29 | NS
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | Losartan | | 227 ± 33 | | 224 ± 31 | NS
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | Mean triglycerides (mg/dL):
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | | | [underlined: Baseline] | | [underlined: 12 wk] | [underlined: p-value]
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | Trandolapril | | 128 ± 59 | | 125 ± 57 | NS
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | Losartan | | 120 ± 51 | | 123 ± 50 | NS
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: Mean FBG (mg/dL):
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | | | [underlined: Baseline] | | [underlined: 12 wk] | [underlined: p-value]
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | Trandolapril | | 92 ± 10 | | 89 ± 10 | NS
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | Losartan | | 93 ± 9 | | 92 ± 10 | NS
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | Mean glucose infusion rate (GIR) (mg/min/kg):
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | | | [underlined: Baseline] | | [underlined: 12 wk] | [underlined: p-value]
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | Trandolapril | | 6.67 ± 0.56 | | 7.99 ± 0.65 | < 0.05
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | Losartan | | 6.74 ± 0.47 | | 6.96 ± 0.50 | NS
Fogari, Zoppi, Preti, et al., 2001 #1580 | | | | | | | p = significant (but not specified) for between-group comparison 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Formosa, Bellomo, Iori, et al., 2009 #1655 | Geographical location: Rome, Italy Study dates: NR Funding source: None Interventions:; 1. Telmisartan: 40 mg/d. Increased to 80 mg/d at week 4, if indicated.; 2. Valsartan: 80 mg/d. Increased to 160 mg/d at week 4, if indicated.; 3. Ramipril: 2.5 mg/d. Increased to 5 mg/d at week 2, if indicated, and then to 10 mg/d at week 4, if indicated.; Were additional anti-hypertension medications allowed: NR If Yes to above, was this done: NR Study design: Other: Prospective and open-label Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: NR Washout period(s): NA Duration of treatment: 12 weeks Duration of post-treatment followup: NA | Number of patients: N = 60; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: NR (20 patients allocated to each intervention group, but unclear if randomly assigned); - Began treatment: 20; - Completed treatment: NR; - Withdrawals/losses to followup: NR; Age: Mean (SD): NR Median: NR Range: All > 65 years Sex (n [%]): Female: NR Male: NR Race/ethnicity (n [%]): NR Baseline blood pressure: Average of 2-3 readings while sitting, after resting for 5 minutes, for baseline measure. Outcomes measured by 24-hr AMBP. Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria:; - HTN grades 1, 2, or 3 according to ESH/ESC 2007 Guidelines; - Metabolic syndrome (diagnosed according to the guidelines of the National Cholesterol Education Program Adult Treatment Panel III, proposed by the AHA in 2005); Exclusion criteria:; - History of coronary illness, cardiac failure, or stroke; - Hepatic or renal insufficiency or with secondary HTN; - Use of pharmaceutical products which might influence BP such as β-agonists and antagonists, nitroglycerine, theophylline, inhibitors of monoamine oxidase, phenothiazine, tricyclic antidepressants and other antihypertensive drugs | | | | | 1) Blood pressure: Repeat ABPM after 12 weeks therapy (compared with baseline ABPM): [underlined: Average BP reduction in the 24 hrs between one administration of the drug and the next:] Telmisartan: 13.8 (SBP); 9.5 (DBP) Valsartan: 11.5 (SBP); 8.0 (DBP) Ramipril: 11.8 (SBP); 7.5 (DBP) [underlined: Average BP reduction in the first 18 hrs of the interval:] Telmisartan: 14.55 (SBP); 9.9 (DBP) Valsartan: 13.2 (SBP); 8.8 (DBP) Ramipril: 13.0 (SBP); 8.3 (DBP) [underlined: Average BP reduction in the last 6 hrs of the interval:] Telmisartan: 11.7 (SBP); 8.3 (DBP) Valsartan: 9.0 (SBP); 5.7 (DBP) Ramipril: 8.3 (SBP); 5.3 (DBP) [underlined: Average BP reduction in the last 4 hrs of the interval:] Telmisartan: 12.5 (SBP); 8.5 (DBP) Valsartan: 8.9 (SBP); 5.6 (DBP) Ramipril: 8.5 (SBP); 5.4 (DBP) 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | | General comments: None Quality assessment: Overall rating: Poor Comments:; - Appears to be non-random allocation to intervention groups; - Inadequate reporting of patient characteristics, methods, and results; - Inappropriate statistical analysis; Applicability:; - Conducted in Italy; Inadequate reporting of patient recruitment and selection, adherence, and co-interventions

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Franke, 1997 #1581 | Geographical location: Saarlouis, Germany Study dates: NR Funding source: NR Interventions:; - Placebo (n = 65); - Candesartan 4 mg (n = 66); - Candesartan 8 mg (n = 68); - Candeartan 12 mg (n = 65); - Enalapril 10 mg (n = 71); No dose titration; no co-interventions Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: Yes; Was allocation concealment adequate?: NR Baseline/run-in period: Washout of at least 2 weeks, followed by 2-week placebo run-in Duration of treatment: 12 weeks Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 364; - Began treatment: NR; - Completed treatment: NR; - Withdrawals/losses to followup: NR (11 due to AEs, rest uncertain); - ITT population = 335; Age: Mean (SD): NR Median: NR Range: NR Sex (n [%]): NR Race/ethnicity (n [%]): NR Baseline blood pressure: NR Seated trough BP measured using a fully automated device (Bosotron 2) Baseline values NR Concurrent medications (n [%]): NR; concomitant treatment with other antihypertensives not permitted Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria:; - Age 18-70 yr; - Mild-to-moderate essential hypertension (sitting DBP 95-114 mmHg); Exclusion criteria: None specified | | | | | 1) Blood pressure: Baseline BP values NR (except DBP in Figure 1) Mean post-treatment BP values NR Mean changes (± SD) in seated trough DBP (mm Hg) at 12 wk: Candesartan 4 mg (n = 66): -8.4 ± 10.5 Candesartan 8 mg (n = 68): -10.5 ± 9.9 Candesartan 12 mg (n =65): -10.0 ± 10.0 Enalapril 10 mg (n = 71): -10.6 ± 9.8 No between-group statistical results shown Response rates (reduction in seated DBP of ≥ 10 mm Hg and/or seated DBP < 90 mm Hg): Candesartan 4 mg (n = 66): 53.0% Candesartan 8 mg (n = 68): 69.1% Candesartan 12 mg (n =65): NR Enalapril 10 mg (n = 71): 69.0% No between-group statistical results shown 2) Rate of use of a single antihypertensive agent for BP control: No other antihypertensives permitted 3) Mortality: NR 4) Morbidity: NR 5) Safety: 186 adverse events, equally distributed among all groups Patients experiencing ≥ 1 AE: Candesartan groups: 28-33% Enalapril: 35% Withdrawals due to AEs: 11 (treatment groups not specified) 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | | General comments:; - Short report with minimal details; Quality assessment: Overall rating: Poor Comments:; - Extremely brief, few details; Applicability:; - Minimal information provided about study population, recruitment sites, etc.

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | Geographical location: NR Study dates: June 1999-Dec 2001 Funding source: NR Interventions: Multi-therapy trial (nifedipine, amlodipine, atenolol, nebivolol, telmisartan, and perindopril); total study was 40 normotensive controls and 180 treated patients; - Telmisartan 80 to 160 mg (n = 29); - Perindopril 2 to 4 mg (n = 28); HCTZ 12.5 mg added if needed to each compound Study design: RCT, parallel-group Blinding:; - Patients: NR; - Providers: NR; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: None Duration of treatment: 6 months Duration of post-treatment followup: NR | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 180; - Began treatment: 180; - Completed treatment: 168; - Withdrawals/losses to followup: 12, all due to treatment failure (required additional drugs beyond those specified in study protocol); Age: Mean (SD): 50.5 ± 10 Median: NR Range: NR Sex (n [%]): Female: 22/57 = 37% Male: 36/57 = 63% Race/ethnicity (n [%]): NR Baseline blood pressure: Mean of 3 measurements taken at 3-min intervals using an automatic digital device (Omron HEM-705CP) | | | | | 1) Blood pressure: At 6 months: | | | | | | General comments:; - Patients in multiple arms with small control group; Quality assessment: Overall rating: Poor Comments:; - No comment on blinding of endpoints; - Study population not well defined (how they were recruited, which patients from which groups dropped out, etc.); - No data on race/ethnicity of subjects; - No data on safety/adverse events; Applicability:; - Limited by few comorbidities and multiple comparisons
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | | | | | | | | | [underlined: Telmisartan] | | [underlined: Perindopril]
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | | | | | | | SBP | | 133 ± 10 | | 134 ± 10
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | | | | | | | DBP | | 86 ± 5 | | 86 ± 6
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | | | | | | | Responders at 6 mo (BP < 140/90 mm Hg): Telmisartan: 22/29 (76%) Perindopril: 22/28 (79%) 2) Rate of use of a single antihypertensive agent for BP control: HCTZ added in 21% of telmisartan patients (6/29) and 25% of perindopril patients (7/28) 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: 164 out of 180 – 16 BP rose too high to continue in study protocol 8) Lipid levels: Total cholesterol:
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | | | [underlined: Telmisartan] | | [underlined: Perindopril] | | | | [underlined: Telmisartan] | | [underlined: Perindopril]
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | | SBP | 151 ± 10 | | 153 ± 9 | | Baseline | | 218 ± 24 | | 214 ± 252
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | | DBP | 100 ± 7 | | 100 ± 6 | | 6 mo | | 216 ± 21 | | 209 ± 21
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: Outpatient clinics Inclusion criteria:; - Patients with essential hypertension who were never treated or had discontinued treatment for HTN; - Non-smokers or < 5 cigarettes per day; - Alcohol consumption < 50 mg/day; Exclusion criteria:; - Diabetes; - Renal dysfunction; - Total cholesterol > 240
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | | | | | | | HDL:
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | | | | | | | | | [underlined: Telmisartan] | | [underlined: Perindopril]
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | | | | | | | Baseline | | 53 ± 15 | | 53 ± 11
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | | | | | | | 6 mo | | 52 ± 14 | | 53 ± 9
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | | | | | | | LDL:
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | | | | | | | | | [underlined: Telmisartan] | | [underlined: Perindopril]
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | | | | | | | Baseline | | 136 ± 16 | | 131 ± 18
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | | | | | | | 6 mo | | 134 ± 17 | | 128 ± 15
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | | | | | | | 9) Progression to type 2 diabetes: Plasma glucose levels remained essentially unchanged (see immediately below) 10) Markers of carbohydrate metabolism/diabetes control: Plasma glucose:
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | | | | | | | | | [underlined: Telmisartan] | | [underlined: Perindopril]
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | | | | | | | Baseline | | 97 ± 8 | | 96 ± 7
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | | | | | | | 6 mo | | 97 ± 8 | | 97 ± 5
Ghiadoni, Magagna, Versari, et al., 2003 #1584 | | | | | | | 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Gregoire, Moisan, Guibert, et al., 2001 #1585 | Geographical location: 173 pharmacies across Canada Study dates: Feb 1996-Oct 1997 Funding source: Merck Frosst Canada Interventions:; - Losartan (n = 80); - ACEI (n = 369); - CCB (n = 214); Study design: Prospective cohort study Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: Yes (research assistants unaware of study's objectives telephoned participants); Was allocation concealment adequate?: NR Baseline/run-in period: NA Duration of treatment: NR Duration of post-treatment followup: 3 months (assessments at baseline, 1mo, and 3mo) | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: NA; - Began treatment: 692 recruited; - Completed treatment: 663; - Withdrawals/losses to followup: 29 (9 lost to followup, 20 discontinued before end of study for reasons other than AEs); Age: Mean (SD): 58.3 Median: NR Range: 20.4-87.7 Sex (n [%]): Female: 369 (55.7%) Male: 294 (44.3%) Race/ethnicity (n [%]): NR Baseline blood pressure: NR Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: 173 pharmacies in Canada Inclusion criteria:; - HTN patients ≥ 18 yr; - Received 1^st^ prescription for losartan, ACEI, or CCB as hypertensive monotherapy; Exclusion criteria:; - Pregnant women; - Taking other anti-HTN meds; - Taking meds for CHF or angina; - Previously given samples of study medication by their physicians | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: ≥ 1 AE related to antihypertensive medication: Losartan: 42/80 (52.5%) ACEI: 222/369 (60.2%) CCB: 149/214 (69.6%) Odds of reporting an AE were significantly higher among patients treated with an ACEI (adjusted odds ratio = 1.78; 95% CI, 1.02 to 3.12) or a CCB (2.65; 1.47 to 4.78) than among patients treated with losartan. Estimates adjusted for age, sex, level of education, number of symptoms due to health problems pereived the week prior to entering the study, prior use of antihypertensive drugs, current use of any other medication, insurance coverage, and duration of hypertension). 6) Specific adverse events: Specific AEs (numbers are n [%]): | | | | | | General comments:; - Obvious limitations from prospective cohort design with no info on those screened but not included; - Statistically significant differences at baseline between 3 groups with respect to proportion who were “new users” vs. “discontinuers” and numbers who switched previous medication due to AEs and uncontrolled hypertension; - No data on BP; Quality assessment: Overall rating: Poor Comments:; - Numbers screened and eligible NR; - AEs relatively well reported; - Adjustment generally good, but lacks adjustment for comorbid conditions (e.g., CHF) which could confound presence of AEs; Applicability:; - No assessment of severity of disease or comorbidities; - No adjustment or evaluation for comorbitiies or severity of disease; - Patients selected by pharmacies; - No blood pressure data
Gregoire, Moisan, Guibert, et al., 2001 #1585 | | | | | | | | | | [underlined: Losartan] | [underlined: ACEI] | [underlined: CCB]
Gregoire, Moisan, Guibert, et al., 2001 #1585 | | | | | | | Dizziness | | | 16 (20) | 49 (13.3) | 51 (23.8)
Gregoire, Moisan, Guibert, et al., 2001 #1585 | | | | | | | Headache | | | 11 (13.8) | 53 (14.4) | 49 (22.9)^*^
Gregoire, Moisan, Guibert, et al., 2001 #1585 | | | | | | | Dry cough | | | 4 (5.0) | 55 (14.9)^*^ | 5 (2.3)
Gregoire, Moisan, Guibert, et al., 2001 #1585 | | | | | | | Tiredness | | | 4 (5.0) | 23 (6.2) | 15 (7.0)
Gregoire, Moisan, Guibert, et al., 2001 #1585 | | | | | | | Nausea | | | 2 (2.5) | 19 (5.1) | 17 (7.9)^*^
Gregoire, Moisan, Guibert, et al., 2001 #1585 | | | | | | | Dry mouth | | | 4 (5.0) | 19 (5.1) | 11 (5.1)
Gregoire, Moisan, Guibert, et al., 2001 #1585 | | | | | | | Swollen ankles | | | 2 (2.5) | 1 (0.3) | 27 (12.6)^*^
Gregoire, Moisan, Guibert, et al., 2001 #1585 | | | | | | | ^*^Adjusted odds of experiencing AE significantly greater than with losartan (see Table 3 for details) 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Guntekin, Gunes, Tuncer, et al., 2008 #77 | Geographical location: Van, Turkey Study dates: NR Funding source: NR Interventions:; - Quinapril 20 mg/day (n = 18). If optimal BP not achieved after 14 days, dose increased up to 40 mg twice daily.; - Irbesartan 150 mg/day (n = 20). If optimal BP not achieved after 14 days, dose increased up to 300 mg/day.; Were additional anti-hypertension medications allowed: No, but patients requiring additional meds were excluded post-randomization Study design: RCT, parallel-group Blinding:; - Patients: NR (probably not); - Providers: NR (probably not); - Assessors of outcomes: Yes, but only for ECG- and echo-measured outcomes; Was allocation concealment adequate?: NR Baseline/run-in period: NA Duration of treatment: 12 months Duration of post-treatment followup: No data reported after 12-month treatment period | Number of patients: N = 38; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 65; - Began treatment: 65; - Completed treatment: 38; - Withdrawals/losses to followup: 27 total: 12 lost to followup; 6 non-compliant; 9 required additional therapy; Age: Mean (SD): 56.5 ± 11 Sex (n [%]): Female: 26 (68.4%) Male: 12 (31.6%) Race/ethnicity (n [%]): NR Baseline blood pressure: Seated, resting with mercury manometer. Highest of two arms used. Quinapril: 198.9/117.5 (SD 19.1/13.8) Irbesartan: 198.0/116.7 (SD 16.7/9.5) Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): Smoking: Quinapril: 3 (16.6) Irbesartan: 4 (20.0) Hyperlipidemia: Quinapril: 6 (33.1) Irbesartan: 5 (25.0) Recruitment setting: NR Inclusion criteria: New diagnosed hypertension Exclusion criteria:; - Systolic BP > 240 mmHg and diastolic BP > 130 mmHg; - Secondary HTN; - AF, left bundle branch block, ventricular tachycardia or frequent ventricular premature beats; - Moderate to severe valvular disease; - Atrial enlargement; - LVEF ≤ 50%; - Hepatic or renal failure; - Chronic obstructive lung disease; - DM; - Known or suspected CAD as assessed by medical history and symptoms; - Estimated pulmonary artery systolic pressure (PASP) > 30 mmHg; - Beta-blocker or anti-arrhythmic drug use for any reason (e.g. migraine, analgesia, seizure, etc.); - Patients requiring further antihypertensive medication beyond study dosages to achieve BP of < 140/90 mmHg were also excluded. | | | | | 1) Blood pressure: P values for between-group differences not reported (“no significant differences between groups”). 6- and 12-month BP compared to baseline P < 0.001 for all readings 6 months (SD): Quinapril: 157.6/90.5 (10.6/5.9) Irbesartan: 156.7/91.7 (12.3/6.1) 12 months (SD): Quinapril: 145.5/90.3 (12.9/8.6) Irbesartan: 149.5/91.5 (14.7/7.9) 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: No significant between-group difference (p values and data not reported). Both reduced posterior wall thickness (data not reported) Quinapril: p = 0.004 Irbesartan: p = 0.016 12) Creatinine/GFR: NR 13) Proteinuria: NR 14) Atrial fibrillation: NR, but data on P-wave duration and P-wave dispersion reported as well | | | | | | General comments: Primary focus on ECG changes Quality assessment: Overall rating: Poor Comments:; - Limited description of protocol; - Analysis was per-protocol and not ITT; Applicability:; - Looks like 65 actually randomized, but only report data on 38 completing the trial; therefore, was per protocol analysis (not ITT); - Limited reporting on protocol, including BP measurement, degree of dose titration in each arm, patient recruitment; - Small study done only in Turkey

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Hasford, Mimran, and Simons, 2002 #1587 | Geographical location: France, Germany, and UK Study dates: Initial antihypertensive prescription given Oct 1997-Sep 1998; patients followed retrospectively for 1 yr Funding source: Sanofi-Synthelabo and Bristol-Myers Squibb Interventions: Monotherapy with one of the following single agents:; - ACEIs: 333; - Irbesartan: 380; - Losartan: 188; - Valsartan: 69; - Candesartan: 82; - Eprosartan: 35; - Beta-blockers (BBs): 441; - Calcium channel blockers (CCBs): 466; - Diuretics: 422; Dose titration and co-interventions: Dose titration of initial medication allowed Study design: Retrospective cohort database study Matched those initially not prescribed irbesartan to those prescribed irbesartan by diabetes, angina, CVA, CHF, MI Blinding:; - Patients: NA; - Providers: NA; - Assessors of outcomes: NA; Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: 1-yr follow up after identification Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: 3026; - Eligible for inclusion: 2416; - Randomized: NA; - Began treatment: NA; - Completed treatment: NA; - Withdrawals/losses to followup: NR; Age: Mean (SD): 60.3 Median: NR Range: NR Sex (n [%]): Female: 1269 (54%) Male: 1147 (46%) Race/ethnicity (n [%]): NR, presumably 100% Caucasian Baseline blood pressure: Method of assessing BP not described | | | | | 1) Blood pressure: BP reduction not a predefined study outcome Minimal results reported for subgroup of all patients with on-treatment BP data (n = 717); precise timepoint(s) of BP measurement(s) not specified; not clear whether restricted to patients who persisted with their original monotherapy General estimating equation (GEE) analysis showed that, in above-described subgroup, patients who were originally prescribed irbesartan had a greater average decrease in SBP (5.91 mm Hg; p = 0.053) and DBP (4.10 mm Hg; p = 0.090) than patients who were initially prescribed losartan and a greater average decrease in SBP (4.95 mm Hg; p = 0.022) and DBP (3.59 mm Hg; p = 0.053) than patients who were initially prescribed any of the remaining agents 2) Rate of use of a single antihypertensive agent for BP control: Assessed on basis of prescriptions filled By 1 yr: 46.8% persisted with initially prescribed monotherapy (see below, under Persistence/adherence) 12.9% (9% irbesartan, 8% losartan, 13.6% all other agents) had switched to a different single agent 23.8% had been prescribed adjunctive antihypertension treatment in addition to initially prescribed med (16.1% irbesartan, 24.5% losartan, 25.3% all other agents) 3) Mortality: NR 4) Morbidity: NR 5) Safety: 12.9% overall (9% irbesartan, 8% losartan, 13.6% all other agents) switched to another agent and 16.5% (14.2% irbesartan, 22.9% losartan, 16.6% all other agents) discontinued all antihypertensive therapy, but not clear whether this had to do with efficacy or AEs or something else 6) Specific adverse events: NR 7) Persistence/adherence: Persistence status determined on basis of filled prescriptions See outcome 2, above, for overall persistence rates Persistence by treatment group (defined as percentage of patients who remained on their initially prescribed monotherapy at 1 yr): | | | | | | General comments: None Quality assessment: Overall rating:Fair Comments:; - Does not report those who were lost from the system at 1 yr; - Outcome measured not useful (lumped together multiple reasons for not being on monotherapy after 1 yr); Applicability:; - Does not report prevalence of the comorbidities patients were matched on (diabetes, angina, CVA, CHF, MI)
Hasford, Mimran, and Simons, 2002 #1587 | | | [underlined: SBP] | | [underlined: DBP] | | | | | [underlined: Persistence]
Hasford, Mimran, and Simons, 2002 #1587 | | ACEIs | 159.8 ± 22.5 | | 94.6 ± 14.1 | | ACEIs | | | 42%
Hasford, Mimran, and Simons, 2002 #1587 | | Irbesartan | 164.3 ± 22.4 | | 93.5 ±16.7 | | Irbesartan | | | 60.8%^*^
Hasford, Mimran, and Simons, 2002 #1587 | | Losartan | 160.4 ± 19.5 | | 91.4 ± 13.8 | | Losartan | | | 44.7%
Hasford, Mimran, and Simons, 2002 #1587 | | Other ARBs | 164.7 ± 21.8 | | 95.9 ± 20.6 | | Other ARBs | | | 51.3%
Hasford, Mimran, and Simons, 2002 #1587 | | BBs | 162.2 ± 23.6 | | 94.4 ± 14.4 | | BBs | | | 49.7%
Hasford, Mimran, and Simons, 2002 #1587 | | CCBs | 162.9 ± 22.1 | | 93.6 ± 17.5 | | CCBs | | | 43.6%
Hasford, Mimran, and Simons, 2002 #1587 | | Diuretics | 160.7 ± 20.4 | | 93.8 ± 12.6 | | ^*^p ≤ 0.001 for irbesartan vs. diuretics, ACEIs, CCBs, BBs, and losartan; p ≤ 0.009 for irbesartan vs. other ARBs 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Hasford, Mimran, and Simons, 2002 #1587 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: Database study from a health database maintained in UK, France, and Germany that covers “hundreds” of practices that “represent the characteristics of the general medicine practices in each country” Inclusion criteria:; - Newly diagnosed hypertension (< 1 yr); - Initial therapy with single agent; Exclusion criteria:; - Hypertension > 1 yr; - Initial prescription for dual agents

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166 | Geographical location: 309 practices of General Practitioners and Internists throughout Germany Study dates: Sep 2000 – May 2001 Funding source: “Completely independent of pharmaceutical sponsors” Interventions: Compared medications as a class: Diuretics Beta blockers Calcium antagonists ACEIs AIIRA (ARBs) Were additional anti-hypertension medications allowed: Yes If Yes to above, was this done: Observational study, so determined by clinician Study design: Retrospective cohort Blinding: No Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: Patients followed for up to 3years after 1^st^ antihypertension prescription Duration of post-treatment followup: NA | Number of patients: N = 13,763; - Screened for inclusion: NR; - Eligible for inclusion: 13,763; - Randomized: NA; - Began treatment: 13,763; - Completed treatment: See results; - Withdrawals/losses to followup: NA (inclusion required at least 3yrs f/u data); Age: Mean (SD): 65 Sex (n [%]): Female: 7707 (56%) Male: 6056 (44%) Race/ethnicity (n [%]): NR Baseline blood pressure: NR Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): Diabetes: 4020 (29.2%) CHD: 4628 (33.6) Lipid disorders: 7135 (51.8) Obesity: 1616 (11.7) Diabetes and lipid disorders: 2564 (18.6) Recruitment setting: Record abstraction from IMS Disease Analyzer; all patients seen in German health care system Inclusion criteria:; - Newly diagnosed with HTN and had been prescribed an initial treatment with either monotherapy or a specified free or fixed combination of two antihypertensive drugs; - Required to have followup data for 3 years; Exclusion criteria: NR | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: Persistence with initial drug class – median days, year 1, 2, 3 | | | | | | General comments: Not clear that all prescriptions were for hypertension (patient just had to have a recent diagnosis of hypertension). Several of these medications have other indications. Quality assessment: Overall rating: Poor Comments: Provides some useful information in estimating the possible range of medication persistence. Would be good to see results in the context of other observational studies on persistence, as seems unlikely that numbers reported here reflect discontinuation due to intolerability or side effects. Applicability:; - Retrospective cohort with low-quality data provides limited information about reasons for discontinuation (doctor-based decision vs. patient-based); - Unclear that all meds were used for hypertension. The numbers for diuretics in particular suggest these may have been used for short-term needs (e.g., volume overload); - Number discontinuing surprisingly low
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166 | | | | | | | | | Med days | % at year 1 | % at year 2 | % at year 3
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166 | | | | | | | ACEI | | 98 | 28.2 | 18.6 | 14.0
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166 | | | | | | | ARB | | 100 | 26.4 | 15.3 | 10.6
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166 | | | | | | | ARB Comb | | 173 | 35.6 | 24.4 | 17.7
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166 | | | | | | | Other+ ACEI | | 0 | 12.9 | 5.6 | 3.2
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166 | | | | | | | Persistence with any drug class – median days, year 1, 2, 3
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166 | | | | | | | | | Med days | % at year 1 | % at year 2 | % at year 3
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166 | | | | | | | ACEI | | 137 | 32.5 | 22.1 | 17.1
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166 | | | | | | | ARB | | 168 | 32.2 | 19.2 | 14.0
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166 | | | | | | | ARB Comb | | 208.5 | 39.5 | 26.8 | 19.6
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166 | | | | | | | Other+ ACEI | | 392.5 | 52.3 | 37.5 | 31.2
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166
Hasford, Schroder-Bernhardi, Rottenkolber, et al., 2007 #166 | | | | | | | Also presents data as frequency of < 4 prescriptions within 3 years or the persistence rates after 3 years 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Hermida, Ayala, Khder, et al., 2008 #24 | Geographical location: Santiago de Compostela, Spain Study dates: Jan 2005 – Mar 2006 Funding source: Grants from Novartis Pharma AG, Basel Switzerland; Dirección General de Investigación, Ministerio de Educación y Ciencia, Madrid, Spain (SAF2006-6254); Xunta de Galicia, Santiago de Compostela, Spain (PGIDIT03-PXIB-32201PR); Hospital Clinico Universitario, Santiago de Compostela; and Vicerrectorado de Investigación, University of Vigo, Vigo, Spain. The funding bodies had no role in the analysis and interpretation of the data, the writing of the report, or the decision to submit the manuscript for publication. Interventions:; - Valsartan 160 mg daily (n = 79); - Enalapril 20 mg daily (n = 78); Were additional anti-hypertension medications allowed: No Study design: RCT, parallel-group Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: Yes; Was allocation concealment adequate?: Yes Baseline/run-in period: NA Duration of treatment: 16 weeks Duration of post-treatment followup: NA | Number of patients: N = 148; - Screened for inclusion: 244; - Eligible for inclusion: 157; - Randomized: 157; - Began treatment: 157; - Completed treatment:148; - Withdrawals/losses to followup:6 lost to followup (3 each arm); 3 discontinued treatment (2 valsartan, 1 enalapril); Age: Mean (SD): 45.8 (10.7) Sex (n [%]): Female: 64 (43.2%) Male: 84 (56.8%) Race/ethnicity (n [%]): Spanish 148 (100%) Baseline blood pressure: Mean of 6 resting seated clinic BP measurements: Valsartan: 156.0/95.2 (13.2/7.4) Enalapril: 154.2/92.5 (10.8/6.3) Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: Hypertension and vascular risk unit of the Hospital Clinico Universitario, Santiago de Compostela, Spain Inclusion criteria: Age ≥ 18 years and a diagnosis of grade 1 or 2 essential HTN as determined by conventional BP measurement (SBP 140-179 mmHg or DBP 90-109 mmHg) and corroborated by 48-hour ambulatory BP monitoring at the time of recruitment (awake mean BP of > 135/85 mmHg or an asleep mean BP of >120/70 mmHg) Exclusion criteria:; - Pregnant women; - Shift workers; - Heavy drinkers (alcohol intake > 80 g/d), heavy smokers (> 20 cigarettes/d), and heavy exercisers were excluded; - Severe arterial HTN (grade 3: > 180/110 mmHg); - Type 1 DM; - Secondary arterial HTN and concomitant CV disorders (including unstable angina pectoris, heart failure, stroke, life-threatening arrhythmia, nephropathy, and retinopathy), or MI or coronary revascularization within the past year | | | | | 1) Blood pressure: Seated 48-hour trough (last dose of medication was 48 hours before this): Valsartan: 139.5/85.0 (17.1/8.2) Enalapril: 145.9/87.5 (15.4/7.5) P value for SBP = 0.026; for DBP = 0.20 Averaged 24-hour mean ABPM reduction (represents mean 24-hour reduction in BP measured over 48 hrs since last med dose) Valsartan: 13.3/10.5 Enalapril: 8.7/6.1 Unclear if between-group difference is statistically significant for SBP (not labeled in Figure 2, but text suggests it is); between-group difference for DBP P < 0.001 1^st^ 24-hour mean ABPM reduction Valsartan: 12.2/9.7 Enalapril: 11.2/7.8 (no significant difference between groups) Separate data for Awake and Asleep ABPM also reported and were significantly different between the two groups (similar to 24-hour mean). Proportion at goal at end of study for awake, sleep, and mean 24-hour BP Valsartan: 54.1% Enalapril: 39.2% P value for between-group difference = 0.036 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: None 4) Morbidity: NR 5) Safety: See below 6) Specific adverse events: Valsartan: 2 discontinued treatment (1 dizziness and 1 nausea) Enalapril: 1 discontinued treatment (hypertensive crisis) 7) Persistence/adherence: Valsartan: 5 total discontinued Enalapril: 4 total discontinued 8) Lipid levels: Total cholesterol at baseline – mg/dL: Valsartan: 215.5 (SD 33.5) Enalapril: 217.2 (SD 36.3) Total cholesterol at 16 weeks (P between groups = 0.42): Valsartan: 210.3 (35.2) Enalapril: 214.9 (32.2) Triglycerides baseline – mg/dL: Valsartan: 112.8 (57.7) Enalapril: 114.9 (67.6) Triglycerides at 16 weeks (P between groups = 0.90): Valsartan: 107.8 (58.6)^*^ Enalapril: 109.1 (65.3) ^*^p = 0.041 versus baseline 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: Baseline fasting glucose (mg/dL): Valsartan: 97.1 (13.5) Enalapril: 95.7 (12.4) P = 0.53 Fasting glucose at 16 weeks: Valsartan: 97.5 (12.1) Enalapril: 98.5 (12.4) P = 0.60 11) LV mass/function: NR 12) Creatinine/GFR: Baseline creatinine (mg/dL): Valsartan: 0.95 (0.13) Enalapril: 0.92 (0.15) P = 0.55 Creatinine at 16 weeks (mg/dL): Valsartan: 0.95 (0.14) Enalapril: 0.93 (0.14) P = 0.45 13) Proteinuria: NR | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: Very well done study, but most of the data reflect BP 48 hours after last dose and are therefore not directly comparable to the majority of our studies. This basically shows that valsartan lasts longer than enalapril, but isn't necessarily more effective (when both taken regularly). Applicability:; - Data reflect BP 48 hours after last dose and therefore should not be combined with our other BP data. Most useful data point is the 1^st^ 24-hour mean ABPM reduction (as this is directly comparable to other studies).

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Hosohata, Saito, Asayama, et al., 2007 #225 | Geographical location: ~1500 general practitioner's offices throughout Japan Study dates: May 2001 through Feb 2004 Funding source: Grants from the Japan Cardiovascular Research Foundation and the Japan Arteriosclerosis Prevention Fund Interventions: 3×2 factorial design comparing two different target BP ranges and 3 initial antihypertensive drugs. Step program based on control. Initial dose at discretion of treating physician; 1. First step is initial drug monotherapy(CCB, ACEI, ARB); 2. Second step is dose increase of first drug; 3. Third step: If patient not controlled on initial drug, then add diuretic; 4. Fourth step: Patients randomized to add either an alpha blocker or beta blocker; 5. Fifth step: Add any other antihypertensive; Were additional anti-hypertension medications allowed: Yes (as described above) If Yes to above, was this done: Per protocol Study design: RCT, parallel-group Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: Yes; Was allocation concealment adequate?: Yes Baseline/run-in period: NR Duration of treatment: 12 months Duration of post-treatment followup: NA | Number of patients: N = 1687; - Screened for inclusion: 2729; - Eligible for inclusion: NR; - Randomized: 1687; - Began treatment: 1687; - Completed treatment: 971 with 1-year followup; - Withdrawals/losses to followup:54 (20 CCB, 11 ACEI, 23 ARB); Age: Mean (SD): 59.7 ±10 Sex (n [%]): Female: 848 (50.3%) Male: 839 (49.7%) Race/ethnicity (n [%]): NR Baseline blood pressure: Home BP: CCB: 151/90 (14/10) ACEI: 153/90 (13/10) ARB: 151/89 (13/11) Office “casual” BP measured twice by physician: CCB: 157/92 (17/12) ACEI: 156/91 (18/12) ARB: 156/91 (17/11) Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: 1500 general practitioners in Japan Inclusion criteria:; - Age 40-79 years; - Essential HTN; - Not on antihypertensive medication; - Home BP values ≥ 135 SBP or ≥ 85 mmHg DBP; Exclusion criteria:; - Contraindications to any of the medications used; - Pure systolic HTN (SBP ≥ 135, but DBP < 65); - Pure diastolic HTN (SBP < 110 and DBP ≥ 85); - Severe HTN defined as home BP ≥ 180/120 or office BP ≥ 220/125 | | | | | 1) Blood pressure: Home BP measurement 6 months: ACEI group: 135/80 (13/10) ARB group: 134/79 (13/9) 12 months: ACEI group: 134/79 (12/9) ARB group: 132/79 (13/8) Casual BP: 6 months CCB group: 133 (SD 16) ACEI group: 136 (SD 16) ARB group: 133 (SD 17) P = 0.03 for comparison among 3 groups 12 months: Numbers not reported, but not statistically significant Rate of BP control (apparently at 12 months, but this is not completely clear): Less intensive group: CCB: 44% ACEI: 43% ARB: 48% (no significant difference) More intensive group: CCB: 21% ACEI: 19% ARB: 19% 2) Rate of use of a single antihypertensive agent for BP control: Those remaining in Step 1 or 2: CCB: 103 (30%) ACEI: 58 (17%) ARB: 89 (29%) Note: It is unclear in the ACEI arm how authors categorized patients who were intolerant of ACEI, switched to ARB, then were controlled on ARB monotherapy 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: Persistence at 12 months: ACEI: 180/328 (55%) ARB: 266/303 (88%) Difficult to assess switch rates from ACEI to ARB. It appears that at least 102 patients in the ACEI arm switched to an ARB at some point. 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: None Applicability:; - The BP data reflect lowering from multiple medications as a part of protocol, would be wary of directly comparing BP-lowering effects between two agents.; - There was high rate of switch from ACE→ARB. Unclear if this was all due to cough or other AE, and unclear how this was categorized in determining which step patients were listed in.

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Karlberg, Lins, and Hermansson, 1999 #1588 | Geographical location: 22 sites, 2 Denmark, 6 Finland, and 14 Sweden Study dates: NR Funding source: NR Interventions:; - Telmisartan (20, 40-80 mg) (n = 139); - Enalapril (5, 10-20 mg) (n = 139); Titrated to higher dose if mean DBP > 90 at 4-wk intervals until wk 16, then add HCTZ 12.5-25 mg for DBP > 90 Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: 3- to 5-wk double-dummy placebo run-in period to determine eligibility Duration of treatment: 26 wk: 16 wk titration; 10 wk maintenance Duration of post-treatment followup: NR | Number of patients:; - Screened for inclusion: 356; - Eligible for inclusion: NR; - Randomized: 278; - Began treatment: 278; - Completed treatment: 251; - Withdrawals/losses to followup: 36, 2 due to lack of efficacy, 27 due to AEs, 7 for administrative or other reasons (note: reported numbers do not total correctly); - ITT population = 272; Age: Mean (SD): 71.0±4.9 Median: NR Range: NR Sex (n [%]): Female: 160 (58%) Male: 118 (42%) Race/ethnicity (n [%]): NR Baseline blood pressure: Trough BP measured 3 times at 2-min intervals after patient rested in supine position for 5 min using a standard mercury sphygmo-manometer Baseline supine values: | | | | | 1) Blood pressure: Placebo-adjusted mean change from baseline in trough supine BP (mm Hg; means NR): | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: Applicability:; - No real baseline co-morbidity information; - Recruitment strategy not clear, run in period took 20% out; - No data on race/ethnicity of subjects
Karlberg, Lins, and Hermansson, 1999 #1588 | | | | | | | | | | [underlined: Telmisartan] | [underlined: Enalapril] | [underlined: p-value]
Karlberg, Lins, and Hermansson, 1999 #1588 | | | | | | | SBP | | | -22.1 | -20.1 | 0.350
Karlberg, Lins, and Hermansson, 1999 #1588 | | | | | | | DBP | | | -12.8 | -11.4 | 0.074
Karlberg, Lins, and Hermansson, 1999 #1588 | | | | | | | Response rates (trough supine BP, last available assessment): Definition of “response”
Karlberg, Lins, and Hermansson, 1999 #1588 | | | | | | | | | Telmisartan | | Enalapri
Karlberg, Lins, and Hermansson, 1999 #1588
Karlberg, Lins, and Hermansson, 1999 #1588 | | | | | | | DBP < 90 | | 86 (63%) | | 84 (62%)
Karlberg, Lins, and Hermansson, 1999 #1588 | | | | | | | DBP < 90 or decrease ≥ 10 mm Hg vs. baseline | | 96 (71%) | | 93 (68%)
Karlberg, Lins, and Hermansson, 1999 #1588 | | | | | | | SBP reduced ≥ 10 mm Hg vs. baseline | | 95 (70%) | | 91 (67%)
Karlberg, Lins, and Hermansson, 1999 #1588 | | | | | | | Note: Also reports subgroup analyses for:; - Age < 75 vs. ≥ 75; - Male vs. female; Results also reported for ABPM 2) Rate of use of a single antihypertensive agent for BP control: 87 (64%) telmisartan and 84 (63%) enalapril used one agent 3) Mortality: NR 4) Morbidity: Quality of life scales administered, but simply states scores were high at baseline in both groups and did not change during study; no quantitative data 5) Safety: 98/139 patients in each treatment group (71%) experienced ≥ 1 AE. 35 (35%) in the telmisartan group and 52 (37%) in the enalapril group were considered by investigators to have treatment-related AEs. Serious AEs considered by investigators to be treatment-related (number of patients): Telmisartan:; - Glaucoma (1); - Strabismus (1); Enalapril:; - Dizziness, vertigo and chest pain (1); - Constipation (1); - Stroke (1); - Severe disabling Quincke's angioneurotic edema (1); Withdrawals due to AEs: Telmisartan: 11 (7.9%) Enalapril: (11.5%) 6) Specific adverse events: Treatment-related AEs (n [%]; n = 139 each group):
Karlberg, Lins, and Hermansson, 1999 #1588 | | | [underlined: Telmisartan] | | [underlined: Enalapril] | | | | [underlined: Telmisartan] | | [underlined: Enalapril]
Karlberg, Lins, and Hermansson, 1999 #1588 | | SBP | 180.6 ± 18.4 | | 177.4 ± 16.6 | | Any event | | 35 (25.2%) | | 52 (37.4%)
Karlberg, Lins, and Hermansson, 1999 #1588 | | DBP | 101.9 ± 5.2 | | 100.7 ± 5.1 | | Cough | | 9 (6.5) | | 22 (15.8)
Karlberg, Lins, and Hermansson, 1999 #1588 | | Concurrent medications (n [%]): Outside of HCTZ added per protocol, not assessed or mentioned Comorbidities (n [%]): NR (though see Exclusion criteria) Recruitment setting: NR – assume outpatient clinics Inclusion criteria:; - Age ≥ 65 years with mild to moderate HTN; - Mean DBP ≥ 95 and ≤ 114 mmHg at final two consecutive visits of the 3- to 5-wk placebo run-in phase, and if mean supine DBP vary by more than 10 mmHg; Exclusion criteria:; - Known or suspected secondary hypertension; - Hepatic or renal dysfunction; - Bilateral renal artery stenosis or post-renal transplant; - NYHA class III or IV CHF; - Recent MI or CABG; - Clinically relevant arrhythmias; - Clinically significant sodium depletion; - Hypokalemia or hyperkalemia; - Poorly controlled diabetes; - Chronic use of oral anti-coagulants; - High doses NSAIDs or acetaminophen; - Salt substitutes or KCL; - Use of investigational drugs; - Patients with mean supine SBP > 220 or supine DBP > 114 mm Hg at any time during the placebo run-in phase | | | | | Diarrhea | | 6 (4.3) | | 3 (2.2)
Karlberg, Lins, and Hermansson, 1999 #1588 | | | | | | | Dizziness | | 4 (2.9) | | 4 (2.9)
Karlberg, Lins, and Hermansson, 1999 #1588 | | | | | | | HA | | 3 (2.2) | | 4 (2.9)
Karlberg, Lins, and Hermansson, 1999 #1588 | | | | | | | Flatulence | | 2 (1.4) | | 2 (1.4)
Karlberg, Lins, and Hermansson, 1999 #1588 | | | | | | | Nausea | | 2 (1.4) | | 2 (1.4)
Karlberg, Lins, and Hermansson, 1999 #1588 | | | | | | | Increased sweating | | 2 (1.4) | | 2 (1.4)
Karlberg, Lins, and Hermansson, 1999 #1588 | | | | | | | Erythematous rash | | 2 (1.4) | | 2 (1.4)
Karlberg, Lins, and Hermansson, 1999 #1588 | | | | | | | Rhinitis | | 2 (1.4) | | 2 (1.4)
Karlberg, Lins, and Hermansson, 1999 #1588 | | | | | | | Impotence | | 2 (1.4) | | 1 (0.7)
Karlberg, Lins, and Hermansson, 1999 #1588 | | | | | | | 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | Geographical location: Trabzon, Turkey Study dates: NR Funding source: NR Interventions:; - Losartan 50 mg daily (n = 20); - Fosinopril 10 mg daily (n = 10); Dose titration/co-interventions: Amlodipine 5 mg add at 1 mo if BP ≥ 140/85; titrated up to 10 mg if BP still uncontrolled at 2 mo Study design: RCT, parallel-group (open-label) Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: No; Was allocation concealment adequate?: NR Baseline/run-in period: 15-day washout if previously on anti-HTN meds (n = 18) Duration of treatment: 6 mo Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion:; - Eligible for inclusion: 33; - Randomized: 33; - Began treatment: 33; - Completed treatment: 33; - Withdrawals/losses to followup: 0; Age: Mean (SD): 52.9 Median: NR Range: 40-66 Sex (n [%]): Female: 20 (61%) Male: 13 (39%) Race/ethnicity (n [%]): NR Baseline blood pressure: Seated trough BP measured using a sphygmomanometer after a 15-min rest; mean of 3 measurements taken at 5-min intervals | | | | | 1) Blood pressure: Mean seated trough BP at 6 mo: | | | | | | General comments:; - All patients recommended to be on low-protein diet,? benefit/impact; Quality assessment: Overall rating: Poor Comments:; - Inconsistent use of significant digits raises more general suspicions; - Large amounts of missing details; Applicability:; - Patients poorly characterized; - Not clear how many other comorbidities present
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | | | [underlined: Losartan] | | [underlined: Fosinopril]
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | SBP | | 132 ± 10 | | 136 ± 8
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | DBP | | 84 ± 7 | | 84 ± 4
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | All comparisons with baseline statistically significant Between-group p-values NS 2) Rate of use of a single antihypertensive agent for BP control: Patients using adjunctive amlodipine: Losartan: 7 (35%) Fosinopril: 4 (31%) 3) Mortality: No deaths during study 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: Mean total cholesterol (mmol/L):
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | | | | Baseline | 6 mo | p-value
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | Losartan | | | 5.65 ± 1.24 | 5.7 ± 1.25 | NS
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | Fosinopril | | | 5.97 ± 1.3 | 5.34 ± 0.72 | < 0.05
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | Mean triglycerides (mmol/L):
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | | | | [underlined: Baseline] | [underlined: 6 mo] | [underlined: p-value]
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | Losartan | | | 2.17 ± 1.1 | 1.66 ± 0.72 | < 0.05
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | Fosinopril | | | 2.36 ± 1.2 | 1.87 ± 1.0 | < 0.05
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | 9) Progression to type 2 diabetes: NA 10) Markers of carbohydrate metabolism/diabetes control: Mean total glucose (mmol/L):
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | [underlined: Losartan] | | [underlined: Fosinopril] | | | | | [underlined: Baseline] | [underlined: 6 mo] | [underlined: p-value]
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | SBP | 159 ± 21 | | 156 ± 21 | | Losartan | | | 8.93 ± 3 | 7.76 ± 1.96 | NS
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | DBP | 99 ± 11 | | 97 ± 9 | | Fosinopril | | | 9.87 ± 3.4 | 9.327 ± 1.9 | NS
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | Concurrent medications (n [%]): Usual antidiabetic medication continued during trial: | | | | | Mean HbA1c (%):
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | Losartan | | Fosinopril | | | | | [underlined: Baseline] | [underlined: 6 mo] | [underlined: p-value]
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | Oral meds | 13 (65%) | | 9 (69%) | | Losartan | | | 7.53 ± 2.50 | 6.58 ± 1.18 | NS
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | Insulin | 3 (15%) | | 2 (15%) | | Fosinopril | | | 8.15 ± 1.64 | 7.57 ± 1.65 | NS
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | Comorbidities (n [%]):; - 100% with diabetes type 2; Recruitment setting: Internal medicine outpatient clinics of a university hospital Inclusion criteria:; - Type 2 diabetes; - SBP 140-180; Exclusion criteria:; - Albuminuria > 300 mg/day; - Cr Cl < 100 mlLmin; - Taking ACEIs or AT1 blockers | | | | | 11) LV mass/function: NR 12) Creatinine/GFR: Mean creatinine (μmol/L):
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | | | | [underlined: Baseline] | [underlined: 6 mo] | [underlined: p-value]
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | Losartan | | | 78.7 ± 17.7 | 84.8 ± 10.6 | NS
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | Fosinopril | | | 86.6 ± 17.7 | 7 84.8 ± 10.6 | NS
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | Mean creatinine clearance (mL/min):
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | | | | [underlined: Baseline] | [underlined: 6 mo] | [underlined: p-value]
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | Losartan | | | 186.5 ± 68.2 | 122.2 ± 38.3 | < 0.0001
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | Fosinopril | | | 156.0 ± 56.6 | 113.1 ± 36.5 | < 0.05
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | 13) Proteinuria: Mean albumin excretion (mg/day) in subgroup with microalbuminuria:
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | | | | [underlined: Baseline] | [underlined: 6 mo] | [underlined: p-value]
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | Losartan | | | 121 (n = 8) | 54.8 (32.0-264.5) | (8.6-261.0) < 0.05
Kavgaci, Sahin, Onder Ersoz, et al., 2002 #1589 | | | | | | | Fosinopril | | | 154 (N = 7) | 14 (44-300) | (10.6-46.0) < 0.05

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Kloner, Neutel, Roth, et al., 2008 #79 | Geographical location: 75 centers in the US Study dates: NR Funding source: Pfizer, Inc. Interventions:; 1. Quinapril/amlodipine:; - Quinapril 20 mg daily ×4 weeks; - If BP > 130/80 then increase to 40 mg ×4 weeks; - After 8 weeks, if BP < 130/80, then no change; if > 160/100, then removed from study or given open-label amlodipine; - If BP between 130/80 and 160/100, then given amlodipine 5 mg daily × 6 more weeks; - After 14 weeks, If BP > 130/80, then amlodipine increased to 10 mg daily; 2. Quinapril/placebo:; - Quinapril 20 mg daily ×4 weeks; - If BP > 130/80 then increase to 40 mg × 4 weeks; - After 8 weeks, if BP < 130/80, then no change; if > 160/100, then removed from study or given open-label amlodipine; - If BP between 130/80 and 160/100, then given placebo daily × 6 more weeks; - After 14 weeks, if BP > 130/80, then placebo dose daily; 3. Losartan/amlodipine:; - Losartan 50 mg daily ×4weeks; - If BP > 130/80 then increase to 100mg × 4weeks; - After 8 weeks, if BP < 130/80, then no change; if > 160/100, then removed from study or given open-label amlodipine; - If BP between 130/80 and 160/100, then given amlodipine 5 mg daily × 6 more weeks.; - After 14 weeks, if BP > 130/80, then amlodipine increased to 10 mg daily; 4. Losartan/placebo:; - Losartan 50 mg daily × 4weeks; - If BP > 130/80 then increase to 100 mg × 4 weeks; - After 8 weeks, if BP < 130/80, then no change; if > 160/100, then removed from study or given open-label amlodipine; - If BP between 130/80 and 160/100, then given placebo daily × 6 more weeks; - After 14 weeks, If BP > 130/80, then placebo dose daily; Were additional anti-hypertension medications allowed: Yes (as indicated above) If Yes to above, was this done: Per Protocol (see protocol above) Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: 7- to 13-day washout period at front end of trial Duration of treatment: 20 weeks Duration of post-treatment followup: NA | Number of patients: N = 411; - Screened for inclusion: 1222; - Eligible for inclusion: NR; - Randomized: 739; - Began treatment: 739; - Completed treatment:; - 739pts included in safety analysis; - 711pts included in monotherapy efficacy analysis; - 411 patients included in combined therapy efficacy analysis.; - Withdrawals/losses to followup:; - 112 continued on only monotherapy (54 quinapril, 58 losartan); - 113 discontinued monotherapy treatment (54 quinapril, 59 losartan); Age: Mean (SD): 58.4 ± 9.7 Range: 32-80 Sex (n [%]): Female: 179 (43.6%) Male: 232 (56.4%) Race/ethnicity (n [%]): White: 286 (69.6%) Black: 70 (17.0%) Asian: 6 (1.5%) Other: 49 (11.9%) Baseline blood pressure: Seated mercury sphygmomanometer after 10-30min rest. Used average of 2 readings. A third reading was taken when difference of ≥ 10 mmHg between first 2. Mean mmHg (SD): Quinapril monotherapy (n = 364): 149.3/88.3 (11.1/8.6) Losartan monotherapy (n=375): 149.8/88.0 (11.3/9.1) Quinapril/amlodipine (represents those who made it to next titration; n = 96): 148.2/89.1 (10.1/7.9) Quinapril/placebo (n = 103): 149.7/88.3 (10.2/8.0) Losartan/amlodipine (n = 115): 149.9/88.0 (10.9/9.3) Losartan/placebo (n = 97): 152.1/88.9 (11.1/7.3) Concurrent non-hypertension medications (n [%]): 422/431 (97.9%) used at least one other medication Antidiabetic agents (84.0%) Lipid-lowering agents (52.7%) Analgesics (48.3%) Vitamins (29.5%) Antiinflammatories (27.1%) Comorbidities (n [%]): Diabetes 100% Recruitment setting: NR Inclusion criteria:; - Diagnosis of type 2 DM; - On stable glucose-lowering treatment (glycosylated hemoglobin ≤ 9.0%) for at least 2 months; - Patients receiving no antihypertensive treatment had to have an SBP of 140-170 mmHg and/or a DBP of 85-100 mmHg; patients on antihypertensive monotherapy had to have an SBP of 140-155 mmHg and/or a DBP of 85-100 mmHg; patients who were using any antihypertensive fixed-dose combination product were required to have an SBP of 135-150 mmHg and/or a DBP of 80-90 mmHg; patients were not permitted to take any antihypertensive agents other than the study medications for the duration of the trial; Exclusion criteria:; - History of accelerated/malignant HTN; - MI, coronary artery bypass, intracoronary interventions, stroke, or transient ischemic attack within 6 months of screening; - Unstable angina, impending infarction, heart failure, and chronic sustained or uncontrolled cardiac arrhythmias; - Secondary HTN of any etiology; - Renal impairment (serum creatinine >2.0 mg/dL)-Severe hepatic impairment; - History of intolerance/hypersensitivity to CCBs, ARBs, or ACEIs | | | | | 1) Blood pressure: Seated mercury sphygmomanometer after 10-30 min rest. Used average of 2 readings. A third reading was taken when difference of ≥ 10 mmHg between first 2. Attainment of BP goal at 20 weeks (< 130/80) Quinapril/amlodipine: 29/96 (30.2%) Quinapril/placebo: 15/103 (14.6%) Losartan/amlodipine: 29/115 (25.2%) Losartan/placebo: 10/97 (10.3%) No statistically significant difference between quinapril and losartan for BP control (p = 0.25) Mean change in SBP from baseline to week 14 among those on monotherapy (small subgroup of population) Quinapril: -8.0 Losartan: -10.6 P = 0.12 2) Rate of use of a single antihypertensive agent for BP control: Week 4: Quinapril: n = 351 (13.4%) Losartan: n = 359 (14.2%) P = 0.66 Week 8: Quinapril : n = 333 (18.9%) Losartan : n = 342 (22.2%) P = 0.18 3) Mortality: None 4) Morbidity: NR 5) Safety: Only 1 serious adverse event related to study treatment (quinapril monotherapy group). Type of event not reported. Discontinuation due to treatment-related adverse event in ACE v. ARB monotherapy: Quinapril: 11/364 (3%) Losartan: 5/375 (1.3%) P = 0.19 6) Specific adverse events: Lab abnormalities: Quinapril: 2% Losartan: 3% 1 patient in quinapril + placebo had increased Cr more than 1.3 times upper limit of normal. Specific AEs for combined therapy: Headache: Quinapril/placebo: 5 (4.5%) Losartan/placebo: 5 (4.9%) Upper RTI: Quinapril/placebo: 4 (3.6%) Losartan/placebo: 3 (2.9%) Cough: Quinapril/placebo: 3 (2.7%) Losartan/placebo: 0 Peripheral edema: Quinapril/placebo: 1 (0.9%) Losartan/placebo: 2 (2.0%) Dizziness: Quinapril/placebo: 0 Losartan/placebo: 2 (2.0) 7) Persistence/adherence: Quinapril: 54/364 discontinued treatment Losartan: 59/375 discontinued treatment 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: Cr changes only reported for comparison of amlodipine add-on vs. placebo. 13) Proteinuria: NR | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: Complicated post-randomization dose adjustments/titration makes primary comparison more convoluted Applicability:; - The complex protocol with multiple post-randomization titration changes based on BP control makes it difficult to compare ACEI vs. ARB outcomes at time points past 8 weeks. Would therefore be wary about combining data that represents effects among responders vs. non-responders.; - Much of the data focuses on comparison of amlodipine vs. placebo add-on and not useful for this review.

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Koylan, Acarturk, Canberk, et al., 2005 #1590 | Geographical location: Turkey Study dates: May 2000-May 2001 Funding source: NR Interventions:; - Irbesartan (n = 337); - ACE inhibitors (n = 298); - CCB (n = 308); Administered “according to approved prescribing guidelines” (details not provided) Study design: RCT, parallel-group Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: No; Was allocation concealment adequate?: No, consecutive patients allocated to treatment group in order (max of 6 patients/physician) Baseline/run-in period: None Duration of treatment: 6 months Duration of post-treatment followup: NR | Number of patients:; - Screened for inclusion: 1053; - Eligible for inclusion: 998; - Randomized: NA; - Began treatment: 983; - Completed treatment: 872; - Withdrawals/losses to followup: 118 (25 due to AEs; 8 due to lack of efficacy; 85 failed to return); Age: Mean (SD): 52.7 to 54 Median: NR Range: NR Sex (n [%]): Female: 56.6% Male: 43.4% Race/ethnicity (n [%]): NR Baseline blood pressure: BP measured in morning after 15 min of rest in the supine position Baseline values (± SEM): | | | | | 1) Blood pressure: No quantitative data reported. Investigators reported no significant differences among the three treatments for:; - Reduction in supine SBP and DBP values (vs. baseline) at 1, 3, and 6 months; - Percentage of patients with normalized SBP and DBP (≤ 140 mmHg and ≤ 90 mmHg, respectively) at 1, 3, and 6 months; 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: | | | | | | General comments: None Quality assessment: Overall rating: Poor Comments:; - Used supine BP; - Primary objective was to evaluate compliance, not efficacy; Applicability:; - Unusual recruitment strategy that seems highly susceptible to selection bias, as reflected by baseline differences in Table 1
Koylan, Acarturk, Canberk, et al., 2005 #1590 | | | | | | | | | | [underlined: Irbesartan] | [underlined: ACE] | [underlined: CCB]
Koylan, Acarturk, Canberk, et al., 2005 #1590 | | | | | | | Any AE | | | 54 (14.3%) | 76 (25.5%) | 60 (19.5%)
Koylan, Acarturk, Canberk, et al., 2005 #1590 | | | | | | | P = 0.001
Koylan, Acarturk, Canberk, et al., 2005 #1590 | | | | | | | Withdrawals due to AEs: Irbesartan: 0 ACEI: 23/298 (7.7%) CCB: 2/308 (< 1%) 6) Specific adverse events: n (%)
Koylan, Acarturk, Canberk, et al., 2005 #1590 | | | | [underlined: Irbe] | [underlined: ACE] | [underlined: CCB] | | | | [underlined: Irbe] | [underlined: ACE] | [underlined: CCB]
Koylan, Acarturk, Canberk, et al., 2005 #1590 | | Supine | | 160.9 | 159.6 | 160.7 | Ankle edema | | | 3 (<1%) | 5 (1.7%) | 20 (6.5%)
Koylan, Acarturk, Canberk, et al., 2005 #1590 | | SBP | | ± 16.2 | ± 15.2 | ± 14.0 | Constipation | | | 6 (1.6) | 2 (<1) | 10 (3.2)
Koylan, Acarturk, Canberk, et al., 2005 #1590 | | Supine | | 96.2 | 96.5 | 95.9 | Cough | | | 3 (<1) | 28 (9.4) | 4 (1.3)
Koylan, Acarturk, Canberk, et al., 2005 #1590 | | DBP | | ± 7.4 | ± 7.5 | ± 7.2 | Dry mouth | | | 14 (3.7) | 19 (6.4) | 11 (3.6)
Koylan, Acarturk, Canberk, et al., 2005 #1590 | | Concurrent medications (n [%]): None Comorbidities (n [%]): | | | | | Dizziness | | | 4 (1.1) | 7 (2.3) | 5 (1.6)
Koylan, Acarturk, Canberk, et al., 2005 #1590 | | Concurrent medications (n [%]): None Comorbidities (n [%]): | | | | | Headache | | | 7 (1.9) | 12 (4.0) | 7 (2.3)
Koylan, Acarturk, Canberk, et al., 2005 #1590 | | Concurrent medications (n [%]): None Comorbidities (n [%]): | | | | | Nausea | | | 7 (1.9) | 9 (3.0) | 3 (<1)
Koylan, Acarturk, Canberk, et al., 2005 #1590 | | LVH | | | 6.6-8.9% | | Feeling sick | | | 15 (4.0) | 7 (2.3) | 14 (4.5)
Koylan, Acarturk, Canberk, et al., 2005 #1590 | | Angina/previous MI | | | 5.4-6.3% | | Pyrosis | | | 9 (2.4) | 8 (2.7) | 6 (1.9)
Koylan, Acarturk, Canberk, et al., 2005 #1590 | | Prior cor revasc | | | 1.4-2.8% | | Insomnia | | | 6 (1.6) | 7 (2.3) | 8 (2.6)
Koylan, Acarturk, Canberk, et al., 2005 #1590 | | Heart failure | | | <1-1.8% | | 7) Persistence/adherence: A higher proportion of patents receiving irbesartan took their daily dose of medication than ACE or CCB (p = 0.0005) (see Figure 1) 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Koylan, Acarturk, Canberk, et al., 2005 #1590 | | Stroke/TIA | | | 0-1.1%
Koylan, Acarturk, Canberk, et al., 2005 #1590 | | Nephropathy | | | <1-3.6%
Koylan, Acarturk, Canberk, et al., 2005 #1590 | | Periph art disease | | | <1- 2.9%
Koylan, Acarturk, Canberk, et al., 2005 #1590 | | Retinopathy | | | 2.4-2.9%
Koylan, Acarturk, Canberk, et al., 2005 #1590 | | Recruitment setting: Patients recruited by internists or cardiologists at multiple university hospitals Inclusion criteria:; - Age > 18 yr; - Mild-to-moderate HTN (90 ≤ DBP ≤ 110 mm Hg); - Newly diagnosed with HTN or patients on HTN monotherapy for whom a change in treatment was indicated; Exclusion criteria:; - Secondary HTN; - DBP ≥ 110 mmHg; - Currently treated with 2-3 anti-HTN drugs or combo agents; - Pregnant or lactating; - Neurological or mental disorders; - MI or CVA < 6 mo; - Severe renal or liver failure

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Lachaine, Petrella, Merikle, et al., 2008 #117 | Geographical location: Quebec, Canada Study dates: Index dates: Jan 1, 2000 – Dec 31, 2001 Data obtained Jan. 1 – Dec. 31, 2003 Funding source: Pfizer Canada Inc., Kirkland, Canada Interventions: ACEI (n = 1731) ARB (n = 962) CCB (n = 1219) BB (n = 1143) Diuretic (n = 1741) Were additional anti-hypertension medications allowed: Yes If Yes to above, was this done: At discretion of clinician Study design: Other – retrospective cohort study Blinding:; - Patients: NA; - Providers: NA; - Assessors of outcomes: No; Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: NA Duration of post-treatment followup: 2 years | Number of patients: N = 4561; - Screened for inclusion: Random sample of 150,000 from over 3 million; - Eligible for inclusion: 4561; - Randomized: NA; - Began treatment: 4561; - Completed treatment: NA; - Withdrawals/losses to followup: NA; Age: Mean (SD): 68.6 ±12.4 Range: < 40: 97 (2.1%) 40 – 59: 859 (18.8%) 60 – 79: 2841 (62.3%) > 80: 764 (16.8%) Sex (n [%]): Female: 2792 (61.2%) Male: 1769 (38.8%) Race/ethnicity (n [%]): NR Baseline blood pressure: NR Concurrent non-hypertension medications (n [%]): Two meds 32% Three meds 19% Four meds 10% Comorbidities (n [%]): Chronic disease score (mean ± SD) 2.9 ± 2.7 Recruitment setting: Enrollees of Quebec provincial drug plan Inclusion criteria:; - HTN diagnosis; - On anti-HTN med, with first use occurring during index period; - Covered by drug plan for entire study period; Exclusion criteria: Used the anti-HTN drug in 12 months prior to index period | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: 39% (not broken down by treatment) 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: | | | | | | General comments: Analysis of pharmacy database Quality assessment: Overall rating: Good Applicability:; - Pharmacy database does not capture clinical information that may influence choice of prescribed anti-hypertensive or explain reason for starting medication (e.g., CHF, not HTN) or for discontinuation of medication (e.g., formulary issues, not intolerance); - Results not reported for persistence or adherence for single agent only to determine ACEI vs. ARB direct comparison
Lachaine, Petrella, Merikle, et al., 2008 #117
Lachaine, Petrella, Merikle, et al., 2008 #117 | | | | | | | Drug | | Persistence | | Adherence
Lachaine, Petrella, Merikle, et al., 2008 #117
Lachaine, Petrella, Merikle, et al., 2008 #117 | | | | | | | ACEI | | 58.9% | | 64.9%
Lachaine, Petrella, Merikle, et al., 2008 #117
Lachaine, Petrella, Merikle, et al., 2008 #117 | | | | | | | ARB | | 60.9% | | 65%
Lachaine, Petrella, Merikle, et al., 2008 #117
Lachaine, Petrella, Merikle, et al., 2008 #117 | | | | | | | CCB | | 64.3% | | 64.2%
Lachaine, Petrella, Merikle, et al., 2008 #117
Lachaine, Petrella, Merikle, et al., 2008 #117 | | | | | | | BB | | 69.3% | | 60.3%
Lachaine, Petrella, Merikle, et al., 2008 #117
Lachaine, Petrella, Merikle, et al., 2008 #117 | | | | | | | Diuretic | | 52.8% | | 50.9%
Lachaine, Petrella, Merikle, et al., 2008 #117
Lachaine, Petrella, Merikle, et al., 2008 #117 | | | | | | | - Adherence higher in 60-79 year age group; - Adherence lower for patients on 3 or more agents; - Adherence not affected by comorbidity score; - Diuretics lower for persistence and 2-year 80% adherence (p < 0.001 and p < 0.01, respectively) and for combined persistence/adherence (34.2% versus 46.5%; p < 0.01) compared with other anti-HTN drugs; 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Lacourciere, Belanger, Godin, et al., 2000 #1591 | Geographical location: 8 centers in Canada Study dates: NR Funding source: Merck Interventions:; - Losartan 50-100 mg daily (n = 52); - Enalapril 5-20 mg daily (n = 51); Dose titration/co-interventions:; - Losartan: Start at 50 mg daily × 8 wks. If DBP > 85, then increase to100 mg daily. If DBP >85 at week 12, then add HCTZ 12.5 mg daily titrated to 25 mg until DBP ≤ 85 (could then add other BP meds to achieve goal, but not specified by protocol); - Enalapril: Start at 5 mg daily × 4 wk. If DBP > 85, then increase to 10 mg daily. At week 8, if DBP still > 85, then increase to 20 mg daily. At week 12, if DBP still > 85, then add HCTZ 12.5 mg daily and titrate to 25 mg until DBP ≤ 85 (could then add other BP meds to achieve goal, but not specified by protocol); Patients with DBP > 100 at week 20 were discontinued from study. Early titration allowed in patients at week 4 if DBP > 105. Study design: RCT- parallel group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: 2-wk placebo run-in. Was preceded by 7-day wash out of previous HTN meds (14-day wash out of ACEIs) Duration of treatment: 52 wk Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 103; - Began treatment: 102; - Completed treatment: 92; - Withdrawals/losses to followup: 11; Age: Mean: 58.5 Median: NR Range: NR Sex (n [%]): Female: 20 (19.4%) Male: 83 (80.6%) Race/ethnicity (n [%]): Caucasion: 99 (96%) Asian: 3 (3%) Black: 1 (1%) Baseline blood pressure: Trough BP measured using standard mercury sphygmomanometer after 5 min rest; average of 3 measurements: | | | | | 1) Blood pressure: Average of 3 seated trough clinic values (SD): | | | | | | General comments:; - Small study; - No description of recruiting strategy or number of patients screened to generate study sample; - Do not present complete data for many outcomes, only those that are statistically significant; - 2 patients (1 in each group) excluded from analysis due to uncontrolled hypertension; Quality assessment: Overall rating: Fair Comments: See above Applicability:; - Placebo run-in limits assessment of discontinuation rates; - Missing a great deal of data on the number of analyses performed and specific data; they seem to report selectively the statistically significant findings; - Long list of exclusions for patients with CV comorbidities
Lacourciere, Belanger, Godin, et al., 2000 #1591 | | | [underlined: Losartan] | | [underlined: Enalapril] | | | | [underlined: SBP] | | [underlined: DBP]
Lacourciere, Belanger, Godin, et al., 2000 #1591 | | SBP | 162.3 ± 16.2 | | 157.7 ± 15.9 | | Losartan :
Lacourciere, Belanger, Godin, et al., 2000 #1591 | | DBP | 97.2 ± 6.3 | | 95.3 ± 4.8 | | Pre: | | 163.3 ± 16.2 | | 97.2 ± 6.3
Lacourciere, Belanger, Godin, et al., 2000 #1591 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR (all diabetic) Recruitment setting: NR (seems like outpatient clinics) Inclusion criteria:; - DM2 dx at age ≥ 30; - Sitting DBP 90-115; - Urinary albumin excretion 20-350 mcg/min; Exclusion criteria: ^*^ There was a placebo run-in period. Didn't indicate how many were excluded by run-in.; - Suspicion of renovascular disease; - History of malignant htn (SBP>210 mmHg); - Stroke, TIA, or MI in previous 12 months; - Significant heart conduction distubances or arrhythmia; - Unstable angina; - History of heart failure; - Serum Cr ≥ 200 mmol/L; - Serum potassium ≥ 5.5 mmol/L or ≤ 3.5mmol/L; - Treatment with oral corticosteroids; - Concomitant use of agents that may affect BP except B-blockers and nitrates; - Drug or alcohol abuse; - Pregnancy or breast feeding; - Ineffective contraception | | | | | Post (52 wk): | | 148.3 ± 17.1 | | 86.8 ± 9.6
Lacourciere, Belanger, Godin, et al., 2000 #1591 | | | | | | | Enalapril:
Lacourciere, Belanger, Godin, et al., 2000 #1591 | | | | | | | Pre: | | 157.7 ± 15.9 | | 95.3 ± 4.8
Lacourciere, Belanger, Godin, et al., 2000 #1591 | | | | | | | Post (52 wks): | | 145.5 ± 18.2 | | 84.4 ± 8.4
Lacourciere, Belanger, Godin, et al., 2000 #1591 | | | | | | | Clinic BP at other time points measured, but not reported. Also report 24-h ambulatory BP at 4 time points during study (baseline, week 12, 28, and 52) – but only 5 of 8 sites did this. 2) Rate of use of a single antihypertensive agent for BP control: Losartan group on monotherapy – 20/52 (38.5%) Enalapril group on monotherapy – 31/52 (59.6%) 3) Mortality: No deaths 4) Morbidity: No CV events 5) Safety: Withdrawals due to AEs: Enalapril – 1 (cough) Losartan – 2 (1 w/ dyspnea and 1 w/ urticaria) 6) Specific adverse events: Cough: Enalapril – 7 patients (14%) Losartan - 0 patients 7) Persistence/adherence: NR 8) Lipid levels: Total cholesterol difference at 52 wk compared to baseline (pre-/post- values NR): Losartan: 2.1% decrease Enalapril: 4.2% decrease P < 0.05 Also report limited data on LDL for losartan only and triglycerides for enalapril only. 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: HbA1c change at 52 wks compared to baseline (pre-/post- values NR): Losartan: + 0.006 Enalapril: + 0.0025 11) LV mass/function: NR 12) Creatinine/GFR: GFR declined approx 9% in each group by week 52 (P < 0.001 for pre-/post- analysis). Values not given for GFR at 52 wk. 13) Proteinuria: Urine albumin excretion based on average of 3 measurements:
Lacourciere, Belanger, Godin, et al., 2000 #1591 | | | | | | | Losartan:
Lacourciere, Belanger, Godin, et al., 2000 #1591 | | | | | | | Pre: | | 64.1 mcg/min (no SD given)
Lacourciere, Belanger, Godin, et al., 2000 #1591 | | | | | | | Post (52 wk): | | 41.5mcg/min
Lacourciere, Belanger, Godin, et al., 2000 #1591 | | | | | | | Enalapril:
Lacourciere, Belanger, Godin, et al., 2000 #1591 | | | | | | | Pre: | | 73.9mcg/min
Lacourciere, Belanger, Godin, et al., 2000 #1591 | | | | | | | Post (52 wk): | | 33.5 mcg/min
Lacourciere, Belanger, Godin, et al., 2000 #1591 | | | | | | | P-value for pre-post was < 0.001 for both. No significant difference between treatments (no p-value given).

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Lacourciere, Neutel, Davidai, et al., 2006 #287 | Geographical location: 81 U.S. and Canadian sites Study dates: Oct 1, 2002 to July 17, 2003 Funding source: NR Interventions: Forced titration of:; - Ramipril 2.5 mg/5 mg/10 mg (n = 407); - Telmisartan 40 mg/80 mg/80 mg (n = 405); Doses were titrated after 2 weeks, then after 6 weeks, then again after 6 weeks Study design: RCT, parallel-group Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: Yes; Was allocation concealment adequate?: NR Baseline/run-in period: Screening 1-7 days; then patients previously treated with an ACEI, ARB, or diuretic underwent a 4-week run-in period, and all other enrollees underwent a 2-week run-in period with placebo Duration of treatment: 14 wk Duration of post-treatment followup: NR | Number of patients: N = 812; - Screened for inclusion: 1998; - Eligible for inclusion:; - Randomized: 812; - Began treatment: 812; - Completed treatment: 722; - Withdrawals/losses to followup: 90, 35 due to AEs, 12 due to lack of efficacy, 13 lost to followup, 14 “investigator decision”, 18 patient decision (note: reported numbers do not total correctly); Age: Mean (SD): 52.5 ± 9.8 Median: NR Range: NR Sex (n [%]): Female: 269 (33.1%) Male: 543 (66.9%) Race/ethnicity (n [%]): 87.7% white (712) Baseline blood pressure: Seated trough BP measured by manual cuff sphygmomanometer: | | | | | 1) Blood pressure: Seated trough BP at 14 wk: | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments:; - Patients and providers not blinded; Applicability:; - Significant number of limitations to inclusion in the study as evidence by number of screened patients to enrolled
Lacourciere, Neutel, Davidai, et al., 2006 #287 | | | | | | | | | | [underlined: Telmisartan] | [underlined: Ramipril] | [underlined: p-value]
Lacourciere, Neutel, Davidai, et al., 2006 #287 | | | | | | | SBP | | | 139.6 | 143.4 | < 0.0000
Lacourciere, Neutel, Davidai, et al., 2006 #287 | | | | | | | DBP | | | 88.7 | 92.0 | < 0.0001
Lacourciere, Neutel, Davidai, et al., 2006 #287 | | | | | | | SBP response at 14 wk (trough seated SBP < 140 mm Hg or reduction from baseline of ≥ 10 mm Hg): Telmisartan: 70.7% Ramipril: 62.7% p < 0.01 DBP response at 14 wk (trough seated DBP < 90 mm Hg or reduction from baseline of ≥ 10 mm Hg): Telmisartan: 60.5% Ramipril: 46.8% p < 0.01 ABPM outcomes also reported (primary) 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: Severe AEs: Telmisartan: 15 (3. 8%) Ramipril: 30 (7.4%) Serious AEs: 14 patients (treatment group NR), none considered to be drug-related Withdrawals due to AEs: Telmisartan: 12 (3.0%) Ramipril: 23 (5.7%) 6) Specific adverse events: AEs occurring at a rate of ≥ 1% and judged to be drug-related:
Lacourciere, Neutel, Davidai, et al., 2006 #287 | | | [underlined: Telmisartan] | | [underlined: Ramipril] | | | | [underlined: Telmisartan] | | [underlined: Ramipril]
Lacourciere, Neutel, Davidai, et al., 2006 #287 | | SPB | 153.9 ± 12.2 | | 152.5 ± 12.8 | | Peripheral edema | | 4 (1%) | | 0
Lacourciere, Neutel, Davidai, et al., 2006 #287 | | DBP | 99.7 ± 4.2 | | 99.8 ± 4.3 | | Dizziness | | 6 (1.5%) | | 4 (1%)
Lacourciere, Neutel, Davidai, et al., 2006 #287 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: Clinic setting Inclusion criteria:; - Age ≥ 18 yr; - Mild-moderate hypertension at baseline (mean DBP ≥ 95 and ≤ 109 mm Hg measured by manual cuff and 24-hr DBP > 85 mm Hg measured by ABPM [Spacelabs 90207] during the morning, daytime, and nighttime periods; Exclusion criteria:; - Mean seated SBP ≥ 180 or mean seated DBP ≥ 110 mm Hg during any visit of the placebo run-in or if they had secondary hypertension, CHF, stroke within 6 months, PTCA within 3 months, hemodynamically significant valvular heart disease, myocardial obstructive pathologic conditions, or clinical relevant arrhythmias; - Night shift workers excluded; - Excluded for relevant organ system disease (poorly controlled diabetes, significant hepatic, renal dysfunction,; - Any hypersensitivity or reaction (including angioedema) to ACEI or ARB, history of non-compliance, substance abuse, sodium depletion, hypokalemia, or hyperkalemia, hereditary fructose intolerance, bililary tract obstruction
Lacourciere, Neutel, Davidai, et al., 2006 #287 | | | | | | | HA | | 4 (1%) | | 6 (1.5%)
Lacourciere, Neutel, Davidai, et al., 2006 #287 | | | | | | | Cough | | 1 (0.2%) | | 33 (8%)
Lacourciere, Neutel, Davidai, et al., 2006 #287 | | | | | | | 7) Persistence/adherence: Withdrawals and reasons: Telmisartan: Adverse events (n = 12) Lack of efficacy (n = 7) Lost to follow-up (n = 5) Investigator' decision (n = 8) Patient decision (n = 12) Ramipril: Adverse events (n = 23) Lack of efficacy (n = 5) Lost to follow-up (n = 8) Investigator' decision (n = 6) Patient decision (n = 6) 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Larochelle, Flack, Marbury, et al., 1997 #1592 | Geographical location: NR; investigators from Canada, Brazil, S. Africa, US Study dates: NR Funding source: Bristol-Myers Squibb Interventions:; - Irbesartan (n = 121) 150 mg once daily; - Enalapril (n = 61) 20 mg once daily; At end of 1 week if seated DBP was ≥ 90, then titration of irbesartan to 300 mg, enalapril to 40 mg After week 4, if seated DBP was ≥ 90, open-label once-daily adjunctive antihypertensive medications were added (HCTZ 25-50 mg/day, followed by long-acting nifedipine 30-60 mg.day and/or atenelol 50-100 mg/day) Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: Diuretics withdrawn for at least 3 days, other anti-hypertensives for at least 24 hr. Patients with seated DBP > 115-130 entered to double-blind phase Those with DBP ≤ 115 entered a single-blind placebo lead-in period of up to 7 days Duration of treatment: 12 weeks Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 182; - Began treatment: NR; - Completed treatment: NR; - Withdrawals/losses to followup: NR; Age: Mean (SD): NR Median: NR Range: NR Sex (n [%]): Female: 72 (40%) Male: 110 (60%) Race/ethnicity (n [%]): White: 98 (54%) Black: 58 (32%) Other: 26 (14%) Baseline blood pressure: Trough-seated DBP 24 ± 3 hr after ingestion of previous day's medication | | | | | 1) Blood pressure: Reduction in trough seated DBP from baseline at 12 wk: Percentage of patients “normalized” (trough seated DBP < 90 mm Hg) at 12 wk: Irbesartan: 59% Enalapril: 57% p = 0.97 Percentage of “responders” (trough seated DBP normalized or reduced ≥ 10 mm Hg from baseline) at 12 wk: Irbesartan: 100% Enalapril: 98% p = 0.97 2) Rate of use of a single antihypertensive agent for BP control (%): On monotherapy at 12 wk: Irbesartan: 9% Enalapril: 7% Also taking HCTZ: Irbesartan: 24% Enalapril: 18% Taking ≥ 3 adjunctive meds: Irbesartan: 67% Enalapril: 75% 3) Mortality: NR 4) Morbidity: NR 5) Safety: No changes in lab parameters, ECG findings or physical exam findings Patients with AEs (%): Irbesartan: 55% Enalapril: 64% 6) Specific adverse events (%): | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments:; - Setting of study; no description (country? system? center selection? study clinicians?); - No data regarding numbers of patients screened or eligible for inclusion; - Raw numbers not reported, only percentages; Applicability:; - Patient compliance not assessed
Larochelle, Flack, Marbury, et al., 1997 #1592 | | | [underlined: Irbesartan] | | [underlined: Enalapril] | | | | [underlined: Irbesartan] | | [underlined: Enalapril]
Larochelle, Flack, Marbury, et al., 1997 #1592 | | SBP | 176.7 ± 17.8 | | 175.4 ± 15.2 | | Headache | | 17.4% | | 19.7%
Larochelle, Flack, Marbury, et al., 1997 #1592 | | DBP | 119.2 ± 3.9 | | 119.0 + 3.3 | | Dizziness | | 9.1% | | 18.0%
Larochelle, Flack, Marbury, et al., 1997 #1592 | | Concurrent medications (n [%]): NR (though see Exclusion criteria) Comorbidities (n [%]): NR (though see Exclusion criteria) Recruitment setting: NR Inclusion criteria:; - Seated diastolic BP 115-130; - Men and surgically sterile or post-menopausal women > 18 yr; - Signed an informed consent; Exclusion criteria:; - Concomitant disease that would present safety hazards; - Concomitant medications known to affect BP; - Patients with seated BP < 115 at day 7 of wash-out period | | | | | Cough | | 2.5% | | 13.1%^*^
Larochelle, Flack, Marbury, et al., 1997 #1592 | | | | | | | URI | | 9.9% | | 13.1%
Larochelle, Flack, Marbury, et al., 1997 #1592 | | | | | | | ^*^p= 0.007
Larochelle, Flack, Marbury, et al., 1997 #1592 | | | | | | | 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Mackay, Pearce, and Mann, 1999 #1594 | Geographical location: United Kingdom Study dates: Immediate post-marketing period for 4 drugs, through 6 mo followup Enalapril (1985) Lisinopril (1988) Perindopril (1990) Losartan (1995) Funding source: Pharmaceutical companies Interventions:; - Enalapril (dose NR; n = 15,361 analyzed); - Lisinopril (dose NR; n = 12,438 analyzed); - Perindopril (dose NR; n = 9089 analyzed); - Losartan (dose NR; n = 14,522 analyzed); Study design: Prospective cohort Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: No; Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: Up to 6 mo Duration of post-treatment followup: Up to 6 mo | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: NA; - Began treatment: NR; - Completed treatment: 51,410 analyzed; - Withdrawals/losses to followup: NR (except for withdrawals due to cough); Age: Mean (SD): 61.9 (~ 13) Median: NR Range: NR Sex (n [%]): Female: 28,215 (55.7%) Male: 22,478 (44.3%) Race/ethnicity (n [%]): NR Baseline blood pressure: NR Concurrent medications (n [%]): NR Comorbidities (n [%]): Cardiac failure 8.8% Recruitment setting: Initial post-marketing surveillance cohort Inclusion criteria: All patients dispensed incident prescriptions for each drug in the immediate post-marketing period in England; and their prescribing general practitioners were mailed a questionnaire Exclusion criteria: NR, but presumably failure of GP to return questionnaire | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: Patients with cough: | | | | | | General comments:; - Authors suggest most cough associated with losartan is due to carry over from ACEI, since most patients put on losartan were switched for ACEI-related cough; Quality assessment: Overall rating: Poor Comments:; - Non-concurrent time periods for assessment of different drugs; - Assembly of cohort not well-described; Applicability:; - Assessment in first few months of use of new drug products suggests that prescribing patterns may no longer be the same
Mackay, Pearce, and Mann, 1999 #1594
Mackay, Pearce, and Mann, 1999 #1594 | | | | | | | Drug | | | Pts w/ cough | Rate per 1000 pt-mo | 95% CI
Mackay, Pearce, and Mann, 1999 #1594
Mackay, Pearce, and Mann, 1999 #1594 | | | | | | | Enalapril | | | 86 | 3.9 | 3.1 to 4.8
Mackay, Pearce, and Mann, 1999 #1594
Mackay, Pearce, and Mann, 1999 #1594 | | | | | | | Lisinopril | | | 270 | 14 | 13 to 16
Mackay, Pearce, and Mann, 1999 #1594
Mackay, Pearce, and Mann, 1999 #1594 | | | | | | | Perindopril | | | 210 | 16 | 14 to 19
Mackay, Pearce, and Mann, 1999 #1594
Mackay, Pearce, and Mann, 1999 #1594 | | | | | | | Losartan | | | 64 | 3.1 | 2.4 to 4.0
Mackay, Pearce, and Mann, 1999 #1594
Mackay, Pearce, and Mann, 1999 #1594 | | | | | | | Rate ratios for cough, day 8 to 60, compared to losartan:
Mackay, Pearce, and Mann, 1999 #1594
Mackay, Pearce, and Mann, 1999 #1594 | | | | | | | Drug | | | RR crude | RR adj for age and sex | 95% CI
Mackay, Pearce, and Mann, 1999 #1594
Mackay, Pearce, and Mann, 1999 #1594 | | | | | | | Enalapril | | | 1.3 | 1.5 | 1.2 to 2.2
Mackay, Pearce, and Mann, 1999 #1594
Mackay, Pearce, and Mann, 1999 #1594 | | | | | | | Lisinopril | | | 4.6 | 4.8 | 3.6 to 6.5
Mackay, Pearce, and Mann, 1999 #1594
Mackay, Pearce, and Mann, 1999 #1594 | | | | | | | Perindopril | | | 5.3 | 5.7 | 4.2 to 7.6
Mackay, Pearce, and Mann, 1999 #1594
Mackay, Pearce, and Mann, 1999 #1594 | | | | | | | Rate ratios for cough; females compared with males
Mackay, Pearce, and Mann, 1999 #1594
Mackay, Pearce, and Mann, 1999 #1594 | | | | | | | Drug | | | RR crude | RR adj for age | 95% CI
Mackay, Pearce, and Mann, 1999 #1594
Mackay, Pearce, and Mann, 1999 #1594 | | | | | | | Enalapril | | | 1.5 | 1.4 | 0.8 to 2.5
Mackay, Pearce, and Mann, 1999 #1594
Mackay, Pearce, and Mann, 1999 #1594 | | | | | | | Lisinopril | | | 1.6 | 1.6 | 1.2 to 2.2
Mackay, Pearce, and Mann, 1999 #1594
Mackay, Pearce, and Mann, 1999 #1594 | | | | | | | Perindopril | | | 1.6 | 1.6 | 1.2 to 2.1
Mackay, Pearce, and Mann, 1999 #1594
Mackay, Pearce, and Mann, 1999 #1594 | | | | | | | Losartan | | | 1.7 | 1.5 | 0.8 to 2.6
Mackay, Pearce, and Mann, 1999 #1594
Mackay, Pearce, and Mann, 1999 #1594 | | | | | | | 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Malacco, Omboni, Volpe, et al., 2010 #2217 | Geographical location: 102 centers in Italy Study dates: NR Funding source: Laborati Guidotti and Malesci Istituto Farmacobiologico. Interventions:; 1. Olmesartan medoxomil. Initial dose 10 mg/day.; 2. Ramipril. Initial dose 2.5 mg/day.; In both arms, dose was doubled in weeks 2-6 if SBP ≥ 140 or DBP ≥ 90 mm Hg in non-diabetic patients, and if SBP ≥ 130 or DBP ≥ 80 mm Hg in diabetic patients, up to a maximum of 40 mg for olmesartan and 10 mg for ramipril. Were additional anti-hypertension medications allowed: No (by inference, no additional anti-hypertension medications allowed) If Yes to above, was this done: NA Study design: RCT, parallel-group. Non-inferiority design. Blinding:; - Patients: Yes (by inference); - Providers: Yes (by inference); - Assessors of outcomes: Yes (by inference); Was allocation concealment adequate?: NR Baseline/run-in period: 2-week run-in (authors used the term “washout”) period with placebo prior to the 12-week RCT phase for patients previously on anti-hypertension medication Washout period(s): NA Duration of treatment: 12 weeks Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: 1242; - Randomized: 1102; - Began treatment: 1102; - Completed treatment: 980/1102 (89%); - Withdrawals/losses to followup: 122/1102 (11%).; 1081/1102 (98%) patients included in intention-to-treat analysis (olmesartan n = 542; ramipril n = 539) Age: Mean (SD): Olmesartan: 71.7 (5.0) Ramipril: 72.0 (5.0) Median: NR Range: NR Sex (n [%]): Olmesartan: Female: 264 (49%) Male: 278 (51%) Ramipril: Female: 265 (49%) Male: 274 (51%) Race/ethnicity (n [%]): NR Baseline blood pressure: Sitting, resting BP, with mean of 3 readings, 2 minutes apart, reported. All readings taken in the morning, approximately 24 hours after last drug intake. Also 24-hour ambulatory BP monitoring at randomization and final visit in a subgroup of patients (n = 630). Sitting SBP at baseline, mm Hg (SD): Olmesartan: 156 (10) Ramipril: 156 (10) Sitting DBP at baseline, mm Hg (SD): Olmesartan: 91 (7) Ramipril: 90 (7) Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): 20% with diabetes Recruitment setting: 102 outpatient clinics and centers in Italy Inclusion criteria:; - Age 65-89; - Outpatient; - Grade 1 or 2 HTN; - DBP between 90-109 or SBP between 140-179 mm Hg after 2 weeks of washout with placebo; Exclusion criteria: NR | | | | | 1) Blood pressure: Change in sitting SBP at 12 weeks, mm Hg (95% CI): Olmesartan: 17.8 (16.8, 18.9) Ramipril: 15.7 (14.7, 16.8) p = 0.01 Change in sitting DBP at 12 weeks, mm Hg (95% CI): Olmesartan: 9.2 (8.6, 9.8) Ramipril: 7.7 (7.1, 8.3) p = 0.01 Subgroup analyses also reported for ages 65-69 and > 70 years Change in ambulatory SBP at 12 weeks, last 6 hours, mm Hg (95% CI): Olmesartan: 10.5 (11.8, 9.0) Ramipril: 7.3 (8.7,5.9) p = 0.01 Change in ambulatory DBP at 12 weeks, last 6 hours, mm Hg (95% CI): Olmesartan: 6.1 (7.0, 5.3) Ramipril: 45. (5.3, 3.6) p = 0.01 2) Rate of use of a single antihypertensive agent for BP control: Proportion normalized on monotherapy at 12 weeks: Olmesartan: 52.6% Ramipril: 46.0% p = 0.03 3) Mortality: NR 4) Morbidity: NR 5) Safety: A total of 136 (12.3%) patients reported AEs (75 in the olmesartan and 61 in the ramipril groups), for an overall number of 175 AEs (98 in the olmesartan and 77 in the ramipril groups). 33 patients (3.0%) were withdrawn from the study because of AEs (14 in the olmesartan and 19 in the ramipril groups). 6) Specific adverse events: Cough, N (%): Olmesartan: 2 (0.4%) Ramipril: 13 (2.4%) 7) Persistence/adherence: 122 (11%) patients did not complete the protocol for the following reasons: consent withdrawal (n = 42); lost to followup (n = 22); adverse events (n = 20); protocol violation (n = 14); lack of efficacy (n = 11); lack of compliance to study procedures (n = 8); other (n = 5) 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | | General comments: None Quality assessment: Overall rating: Good Comments:; - Well-designed and reported study; - Funded by pharmaceutical company; Applicability:; - Conducted in Italy; - Monotherapy only

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Malacco, Santonastaso, Vari, et al., 2004 #1595 | Geographical location: 88 outpatient centers in Italy Study dates: NR Funding source: Novartis Interventions:; - Valsartan 160 mg (n = 604); - Lisiniopril 20 mg (n = 609); Dose titration and co-interventions: No dose titration; HCTZ 12.5 mg added at 4 wk for non-responders (SBP > 150 or decrease < 20 [if SBP < 180] or decrease < 30 [if SBP ≥ 180]) Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: NR; - Assessors of outcomes: Yes; Was allocation concealment adequate?: Yes Baseline/run-in period: 2-wk placebo run-in Duration of treatment: 16 wk Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 1213; - Began treatment: 1213; - Completed treatment: 1100; - Withdrawals/losses to followup: 113 (32 due to AEs, other causes NR); Age: Mean (SD): 54.1 (10.1) Median: NR Range: 28-78 Sex (n [%]): Female: 578 (48%) Male: 635 (52%) Race/ethnicity (n [%]): White: 100% Baseline blood pressure: Trough seated BP measured 3 times after 5-min rest using mercury sphygmomanometer; mean of 3 readings used Mean baseline values (± SD): | | | | | 1) Blood pressure: Mean BP (± SD) at 16 wk (ITT population): | | | | | | General comments: None Quality assessment: Overall rating: Good Applicability:; - Setting/recruitment/selection NR; - Exclusion criteria strict and vague
Malacco, Santonastaso, Vari, et al., 2004 #1595 | | | | | | | | | Valsartan (n = 594) | | Lisinopril (n = 591) | | General comments: None Quality assessment: Overall rating: Good Applicability:; - Setting/recruitment/selection NR; - Exclusion criteria strict and vague
Malacco, Santonastaso, Vari, et al., 2004 #1595 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Applicability:; - Setting/recruitment/selection NR; - Exclusion criteria strict and vague
Malacco, Santonastaso, Vari, et al., 2004 #1595 | | | | | | | SBP | | 137.2 ± 13.3 | | 136.8 ± 12.2 | | General comments: None Quality assessment: Overall rating: Good Applicability:; - Setting/recruitment/selection NR; - Exclusion criteria strict and vague
Malacco, Santonastaso, Vari, et al., 2004 #1595 | | | | | | | DBP | | 83.9 ± 7.1 | | 83.7 ± 7.0 | | General comments: None Quality assessment: Overall rating: Good Applicability:; - Setting/recruitment/selection NR; - Exclusion criteria strict and vague
Malacco, Santonastaso, Vari, et al., 2004 #1595 | | | | | | | Rates of BP control (SBP ≤ 150 or decrease ≥ 20 [if baseline SBP < 180] or ≥ 30 [if baseline SBP ≥ 180]): Valsartan: 428 (82.6%) Lisinopril: 409 (81.6%) p = NS Also reported: Mean BP at 16 wk for per-protocol population Mean reductions in BP vs. baseline (ITT and per-protocol populations) 2) Rate of use of a single antihypertensive agent for BP control: Valsartan: 79.3% Lisinopril: 78.7% 3) Mortality: No deaths occurred during trial 4) Morbidity: NR 5) Safety: Any drug-related AE: Valsartan: 31/604 (5.1%) Lisinopril: 65/609 (10.7%) p = 0.001 Severe AEs: Valsartan: 3/604 (< 0.5%) Lisinopril: 3/609 (< 0.5%) Withdrawals due to AEs: Valsartan: 9/604 (1.5%) Lisinopril: 23/609 (3.8%) p = 0.01 6) Specific adverse events: Drug-related AEs: | | | | | | General comments: None Quality assessment: Overall rating: Good Applicability:; - Setting/recruitment/selection NR; - Exclusion criteria strict and vague
Malacco, Santonastaso, Vari, et al., 2004 #1595 | | | Valsartan (n = 594) | | Lisinopril (n = 591) | | | | Valsartan (n = 604) | | Lisinopril (n = 609) | | General comments: None Quality assessment: Overall rating: Good Applicability:; - Setting/recruitment/selection NR; - Exclusion criteria strict and vague
Malacco, Santonastaso, Vari, et al., 2004 #1595 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Applicability:; - Setting/recruitment/selection NR; - Exclusion criteria strict and vague
Malacco, Santonastaso, Vari, et al., 2004 #1595 | | SBP | 167.4 ± 10.2 | | 167.2 ± 9.5 | | Cough^*^ | | 6 (1%) | | 44 (7.2%) | | General comments: None Quality assessment: Overall rating: Good Applicability:; - Setting/recruitment/selection NR; - Exclusion criteria strict and vague
Malacco, Santonastaso, Vari, et al., 2004 #1595 | | DBP | 99.3 ± 4.2 | | 99.1 ± 4.3 | | Headache | | 4 (0.7%) | | 9 (1.5%) | | General comments: None Quality assessment: Overall rating: Good Applicability:; - Setting/recruitment/selection NR; - Exclusion criteria strict and vague
Malacco, Santonastaso, Vari, et al., 2004 #1595 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria:; - Age ≥ 18 yrs; - Mild to severe HTN (SBP 160-220 and DBP 95-110); Exclusion criteria:; - Malignant HTN; - TIA, CVA, or MI within 6 months; - Secondary HTN; - CHF; - Clinically relevant arrhythmia; - Clinically significant valvular heart disease; - Liver disease; - Hyperkalemia; - Serum creatinine > 1.5 times normal; - Type 1 diabetes; - Type 2 diabetes with poor glucose control or neuropathy; - Known hypersensitivity to ARB, ACEI, or thiazides; - Pregnant, possibly pregnant, or breastfeeding women; - Women of childbearing age not using birth control | | | | | Vertigo | | 4 (0.7%) | | 1 (0.2%) | | General comments: None Quality assessment: Overall rating: Good Applicability:; - Setting/recruitment/selection NR; - Exclusion criteria strict and vague
Malacco, Santonastaso, Vari, et al., 2004 #1595 | | | | | | | Asthenia | | 3 (0.5%) | | 4 (0.7%) | | General comments: None Quality assessment: Overall rating: Good Applicability:; - Setting/recruitment/selection NR; - Exclusion criteria strict and vague
Malacco, Santonastaso, Vari, et al., 2004 #1595 | | | | | | | Palpitations | | 2 (0.3%) | | 2 (0.3%) | | General comments: None Quality assessment: Overall rating: Good Applicability:; - Setting/recruitment/selection NR; - Exclusion criteria strict and vague
Malacco, Santonastaso, Vari, et al., 2004 #1595 | | | | | | | Hypotension | | 1 (0.2%) | | 3 (0.5%) | | General comments: None Quality assessment: Overall rating: Good Applicability:; - Setting/recruitment/selection NR; - Exclusion criteria strict and vague
Malacco, Santonastaso, Vari, et al., 2004 #1595 | | | | | | | 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | | General comments: None Quality assessment: Overall rating: Good Applicability:; - Setting/recruitment/selection NR; - Exclusion criteria strict and vague

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Malde, Regalado, and Greenberger, 2007 #223 | Geographical location: Chicago, IL Study dates: Jan 1991-May 2004 Funding source: Ernest S. Bazley Grant to Northwestern Memorial Hospital and Northwestern University Interventions: Routine use of ACEI or ARB prior to development of angioedema and presentation to ER Were additional anti-hypertension medications allowed: NR Study design: Other – retrospective cohort Blinding:; - Patients: NA; - Providers: NA; - Assessors of outcomes: NA; Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: Varied, range 1 day to 10 years, mean 1.8 years Time to angioedema presentation after starting ACEI or ARB Mean for 51 patients (years) 1.8 1 month 13 (25%) First week 6 (12%) 1 month to 1 year 18 (35%) 1 year 14 (28%) Duration of post-treatment followup: NA | Number of patients: N = 64; - Screened for inclusion: 278; - Eligible for inclusion: 64; - Randomized: NA; - Began treatment: NA; - Completed treatment: NA; - Withdrawals/losses to followup: NA; Age: Mean (SD): 60.2 Median: 59 Range: 32–92 Sex (n [%]): Female: 38 (60%) Male: 26 (40%) Race/ethnicity (n [%]): AA: 44 (69%) White: 15 (23%) Hispanic: 2 (3%) Other: 3 (5%) Baseline blood pressure: NR Concurrent non-hypertension medications (n [%]): N (%) NSAID or aspirin: 24 (38%) Cyclo-oxygenase 2 inhibitor: 4 (6%) Opiate: 3 (5%) Comorbidities (n [%]): HTN 19 (30%) HTN and DM 9 (14%) CAD or CHF 10 (16%) Unspecified 26 (41%) Recruitment setting: Emergency room Inclusion criteria: Adverse event due to ACEI or ARB consisting of angioedema, urticaria, or anaphylaxis Exclusion criteria: Other types of adverse events | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: Thirteen patients (20%) were admitted to the medical intensive care unit. Of these, 2 were intubated, and no patients required a tracheostomy. There were no fatalities. 5) Safety: NR 6) Specific adverse events: Angioedema: ACEI (n = 61), ARB (n = 3) Women 60% African American 69% Caucasian 23% Hispanics 2% 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | | General comments: Multiple indications for ACEI or ARB Quality assessment: Overall rating: Fair Comments: Limited to single center Applicability:; - Not all study pts had HTN; - Half of study population had other concomitant med that could have also caused angioedema

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Mallion, Bradstreet, Makris, et al., 1995 #1596 | Geographical location: Multicenter, with sites in Italy, Costa Rica, France, Switzerland, New Zealand, Germany, Austria, The Netherlands, and Portugal Study dates: NR Funding source: NR (multiple authors from Merck) Interventions:; - Losartan 50-100 mg (n = 109); - Captopril 50-100 mg (n = 54); Dose titration and co-interventions: Patients started on 50 mg and titrated up to 100 mg if BP not controlled (DBP 90-115 mm Hg) at 6 wk; no co-interventions allowed Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: Yes; Was allocation concealment adequate?: Yes – details not specified Baseline/run-in period: 4-wk placebo run-in Duration of treatment: 12 wk Duration of post-treatment followup: 1 wk without study drugs to determine rebound HTN | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 163; - Began treatment: 163; - Completed treatment: 142; - Withdrawals/losses to followup: 21 (15 due to AEs, 3 lost to followup, 3 not described); Age: Mean (SD): 54.1 Median: NR Range: NR Sex (n [%]): Female: 63 (39%) Male: 100 (61%) Race/ethnicity (n [%]): Caucasian: 145 (89%) Oriental: 2 (1%) Latin American: 9 (6%) Black: 4 (2%) Asian: 3 (2%) Baseline blood pressure: Trough seated BP measured 3 times at 1-min intervals after 5 min rest (instrument not specified); average of 3 readings used | | | | | 1) Blood pressure: Mean BP at 12 wk: | | | | | | General comments:; - Patients withdrawn if DBP not ≥ 95 during placebo run-in period resulting in some potential exclusions; - Primary outcome was change in DBP, but one wonders if this was established a priori since it was the only significant BP change during the study.; - Randomization stratified by degree of hypertension (mild vs. moderate); Quality assessment: Overall rating: Fair Comments:; - Numbers of screened and eligible patients NR; Applicability:; - Minimal racial diversity (89% Caucasian); - Recruitment setting(s) not described; - Minimal comorbidities in study population of hypertensive patients
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | | | | | | | Losartan (n = 109) | | Captopril (n = 51)
Mallion, Bradstreet, Makris, et al., 1995 #1596
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | | | | | SBP | | 149.8 (20.3) | | 151.4 (16.4)
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | | | | | DBP | | 93.9 (9.3) | | 97.9 (9.2)
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | | | | | Adjusted^*^ mean change in BP at 12 wk:
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | | | | | | | Losartan (n = 109) | | Captopril (n = 51) | P-value
Mallion, Bradstreet, Makris, et al., 1995 #1596
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | | | | | SBP | | -9.1 | | -7.9 | NS
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | | | | | DBP | | -9.1 | | ≤ 0.01 | -5.7
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | | | | | ^*^Adjusted for baseline BP BP response rates at 12 wk (DBP < 90 or DBP ≥ 90 with reduction of ≥ 10 from baseline): Losartan: 55/109 (50.5%) Captopril: 15/51 (29%) p ≤ 0.05 Subgroup analyses (no formal statistical testing done): Mean reduction in DBP at 12 wk, age < 65 vs. ≥ 65:
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | Losartan | | Captopril | | | | [underlined: Age < 65] | | [underlined: Age ≥ 65]
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | | | | | Losartan DBP | | -9.4 | | -8.1
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | SBP | 159.3 (16.8) | | 159.4 (16.2) | | Captopril DBP | | -5.1 | | -7.7
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | DBP | 103.1 (5.3) | | 103.7 (5.5) | | Sex “not a significant demographic factor, although DBP reductions were slightly higher in men at all time-points within both treatment groups” 2) Rate of use of a single antihypertensive agent for BP control: NA (no other antihypertensive meds allowed) 3) Mortality: NR 4) Morbidity: NR 5) Safety:
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | Concurrent medications (n [%]):; - Non-study BP meds not permitted; - Allowed acetaminophen, aspirin, NSAIDs; Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria:; - Age ≥ 18 yr; - Mild-to-moderate essential HTN (mean sitting DBP 90-115 before placebo run-in, then 95-115 after 2 and 4 wk on placebo); Exclusion criteria:; - Known hypersensitivity/contraindication (including angioedema, cough) to captopril or other ACEI; - Significant cardiovascular, cerebrovascular, renal/ hepatic disease; - Secondary or malignant HTN; - Recent MI; - Serum K <3.5 or > 5.5 mmol/L or other laboratory values outside of the normal ranges; - Women of child-bearing age if not surgically sterile or using effective contraception
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | | | | | | | Losartan [underlined: (n [%])] | | Captopril [underlined: (n [%])]
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | | | | | ≥ 1 AE | | 42 (38.5%) | | 20 (37.0%)
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | | | | | Withdrawals due to AEs | | 10 (9.2%) | | 5 (9.3%)
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | | | | | Drug-related AEs | | 16 (14.7%) | | 10 (18.5%)
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | | | | | 6) Specific adverse events: AEs occurring in > 4% of patients in either group:
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | | | | | | | Losartan (n = 109) n (%) | | Captopril (n = 54) DRn (%) | DR
Mallion, Bradstreet, Makris, et al., 1995 #1596
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | | | | | Headache | | 8 (7.3) 2 | | 4 (7.4) 3
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | | | | | Nausea | | 6 (5.5) 1 | | 2 (3.7) 2
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | | | | | Dizziness | | 4 (3.7) 1 | | 3 (5.6) 2
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | | | | | URI | | 5 (4.6) 0 | | 0
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | | | | | DR = # AEs considered to be drug-related
Mallion, Bradstreet, Makris, et al., 1995 #1596 | | | | | | | 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Malmqvist, Kahan, and Dahl, 2000 #1597 | Geographical location: 56 centers, locations not reported Study dates: NR Funding source: Astra Hässle AB Interventions:; - Candesartan 8 to 16 mg (n = 140); - Enalapril 10 to 20 mg (n = 146); - HCTZ 12.5 to 25 mg (n = 143); Dose titration/co-interventions: Higher doses used if DBP > 90 mm Hg after 6 wk; no co-interventions Study design: RCT, parallel-group Blinding:; - Patients: Yes (double-dummy); - Providers: NR; - Assessors of outcomes: Yes; Was allocation concealment adequate?: NR Baseline/run-in period: 3- to 6-wk placebo run-in Duration of treatment: 12 wk Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: 512; - Randomized: 429; - Began treatment: 429; - Completed treatment: 404; - Withdrawals/losses to followup: 26 (17 due to AEs, 9 for other reasons); Age: Mean: 57.7 Median: Range: 40 to 70 Sex (n [%]): Female: 100% Male: 0% Race/ethnicity (n [%]): NR Baseline blood pressure: Trough seated BP measured in duplicate, with an interval of at least 1 min, after patient rested in seated position for 5 min Mean baseline values NR Concurrent medications (n [%]): Non-study medication that would affect BP not allowed; no changes permitted to hormone replacement therapy Comorbidities (n [%]): History of habitual smoking: 9% Estrogen replacement: 22% Recruitment setting: NR Inclusion criteria:; - Women age 40-69 yr; - Untreated or treated primary hypertension (seated DBP 95-115) from a mean of 2 measurements at the end of placebo run-in period; Exclusion criteria:; - Secondary or malignant hypertension; - Seated SBP > 200 mm Hg; - MI, stroke, coronary bypass surgery, TIA within prior 6 mo; - Angina, aortic/mitral valve stenosis, heart failure, or arrhythmia; - Insulin-treated diabetes; - Gout; - Severe concomitant disease that may interfere with assessment; - Any condition associated with poor compliance (e.g., drug or alcohol abuse) | | | | | 1) Blood pressure: Mean post-treatment BP values NR Mean change in seated trough BP from baseline to 12 wk (no variance data reported): | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments:; - Mean baseline and post-treatment BP values NR; - Patients withdrawn from study if mean seated SBP > 200 mm Hg or DBP > 110 mm Hg on > 2 occasions in 1 wk; Applicability:; - High loss during placebo run-in period (62/512 initially enrolled); - 100% women; - Exclusion of patients who did not respond to therapy (seated SBP > 200 mm Hg or DBP > 110 mm Hg on > 2 occasions in 1 wk) means that analyzed population is a selected group of those who did respond; leads to bias
Malmqvist, Kahan, and Dahl, 2000 #1597 | | | | | | | | | [underlined: Candesartan] | | [underlined: Enalapril]
Malmqvist, Kahan, and Dahl, 2000 #1597 | | | | | | | SBP | | -19 | | -13
Malmqvist, Kahan, and Dahl, 2000 #1597 | | | | | | | DBP | | -11 | | -9
Malmqvist, Kahan, and Dahl, 2000 #1597 | | | | | | | Mean difference between treatments (candesartan vs. enalapril) in change in seated trough BP from baseline to 12 weeks:
Malmqvist, Kahan, and Dahl, 2000 #1597 | | | | | | | | | [underlined: Mean diff] | | [underlined: 95% CI] | [underlined: P-value]
Malmqvist, Kahan, and Dahl, 2000 #1597 | | | | | | | SBP | | -5.5 | | -9.1 to -1.9 | < 0.01
Malmqvist, Kahan, and Dahl, 2000 #1597 | | | | | | | DBP | | -2.2 | | -3.9 to -0.5 | = 0.01
Malmqvist, Kahan, and Dahl, 2000 #1597 | | | | | | | BP control rates (seated DBP ≤ 90 mm Hg) at 12 wk: Candesartan: 60% Enalapril: 51% p = NS 2) Rate of use of a single antihypertensive agent for BP control: No other antihypertensives permitted 3) Mortality: NR 4) Morbidity: No difference in Psychological General Well-Being, McMaster Overall Treatment Evaluation Questionnaire (data not reported) 5) Safety: Any AEs: Candesartan: 60% Enalapril: 67% 10 serious AEs were reported (treatment groups not specified); none assessed as related to study drug 17/429 randomized patients (4%) withdrew due to AEs; treatment groups not specified 6) Specific adverse events: Number of patients (%):
Malmqvist, Kahan, and Dahl, 2000 #1597 | | | | | | | | | [underlined: Candesartan] | | [underlined: Enalapril]
Malmqvist, Kahan, and Dahl, 2000 #1597 | | | | | | | Respiratory infection | | 12 (8) | | 7 (5)
Malmqvist, Kahan, and Dahl, 2000 #1597 | | | | | | | Fatigue | | 11 (8) | | 7 (5)
Malmqvist, Kahan, and Dahl, 2000 #1597 | | | | | | | Headache | | 10 (7) | | 27 (19)
Malmqvist, Kahan, and Dahl, 2000 #1597 | | | | | | | Dizziness | | 6 (4) | | 10 (7)
Malmqvist, Kahan, and Dahl, 2000 #1597 | | | | | | | Cough | | 0 (0) | | 19 (13)
Malmqvist, Kahan, and Dahl, 2000 #1597 | | | | | | | Palpitations | | 5 (4) | | 0 (0)
Malmqvist, Kahan, and Dahl, 2000 #1597 | | | | | | | 7) Persistence/adherence: Compliance (defined as amount of prescribed medication taken) was between 75 and 125% in all but 2 patients; not reported by treatment group 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Marentette, Gerth, Billings, et al., 2002 #1598 | Geographical location: Saskatchewan, Canada (database including > 90% of provincial residents) Study dates: Jan 1994-Dec 1998 Funding source: Merck Frosst Canada, Ltd. Interventions: Number of patients with data for at least 180 days: ARBs (n = 267) ACEIs (n = 7466) Beta-blockers (n = 4295) CCBs (n = 3200) Diuretics (n = 9623) Alpha-blockers (n = 731) Alpha-agonists (n = 575) Vasodilators (n = 25) Mixed classes (more than 1 class concurrently or sequentially during study period; n = 20,276) Study design: Retrospective cohort study Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: No; Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: NR Duration of post-treatment followup: Patients followed for minimum of 180 days to a maximum of 720 days | Number of patients:; - Screened for inclusion: 51,029; - Eligible for inclusion: 46,458; - Randomized: NA; - Began treatment: NA; - Completed treatment: NA; - Withdrawals/losses to followup: NA; Age (ARBs and ACEIs): Mean: 58 Median: NR Range: 1-85 Sex (ARBs and ACEIs; %): Female: 48.8% Male: 51.2% Race/ethnicity (n [%]): NR Baseline blood pressure: NR Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: Population-based prescription drug database Inclusion criteria:; - ICD-9 code diagnosis of hypertension (401, 402, 403, 404, or 4-digit codes included in these categories); - At least 1 antihypertensive prescription during first 4.5 yr of study period; - No antihypertensive prescription in the 12 mo before the first prescription; Exclusion criteria: None specified | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: Sample sizes at various timepoints: | | | | | | General comments:; - Relatively small number of patients in ARB subgroup; Quality assessment: Overall rating: Fair Comments:; - Non-random allocation to drugs; - No data on comparability of patients on ACEIs versus ARBs; - Funded by pharmaceutical company; Applicability:; - Study period soon after introduction of ARBs; early use may not reflect current use patterns
Marentette, Gerth, Billings, et al., 2002 #1598 | | | | | | | | | [underlined: ARBs] | | [underlined: ACEIs]
Marentette, Gerth, Billings, et al., 2002 #1598 | | | | | | | 180 days | | 267 | | 7466
Marentette, Gerth, Billings, et al., 2002 #1598 | | | | | | | 360 days | | 170 | | 6539
Marentette, Gerth, Billings, et al., 2002 #1598 | | | | | | | 540 days | | 44 | | 5699
Marentette, Gerth, Billings, et al., 2002 #1598 | | | | | | | 720 days | | 3 | | 4826
Marentette, Gerth, Billings, et al., 2002 #1598 | | | | | | | Small ARB sample explained by fact that ARBs not listed in provincial formulary until March 1996. Patient classified as persistent at a given period of observation (180, 360, 540, or 720 days) if patient filled at least one prescription within 90 days of the end of the given period and within 90 days of the end of each prior interval. Extrapolating from Figure 2, persistence was:
Marentette, Gerth, Billings, et al., 2002 #1598 | | | | | | | | | [underlined: ARBs] | | [underlined: ACEIs]
Marentette, Gerth, Billings, et al., 2002 #1598 | | | | | | | 180 days | | 87% | | 75%
Marentette, Gerth, Billings, et al., 2002 #1598 | | | | | | | 360 days | | 85% | | 65%
Marentette, Gerth, Billings, et al., 2002 #1598 | | | | | | | 540 days | | - | | 60%
Marentette, Gerth, Billings, et al., 2002 #1598 | | | | | | | 720 days | | - | | 55%
Marentette, Gerth, Billings, et al., 2002 #1598 | | | | | | | When considering all drug classes, persistence was higher for males and for older ages. Persistence was reported by age for ACEIs (but not ARBs):
Marentette, Gerth, Billings, et al., 2002 #1598 | | | | | | | 1-47 yr: | | | 71.7%
Marentette, Gerth, Billings, et al., 2002 #1598 | | | | | | | 48-57: | | | 76.1%
Marentette, Gerth, Billings, et al., 2002 #1598 | | | | | | | 58-66: | | | 74.5%
Marentette, Gerth, Billings, et al., 2002 #1598 | | | | | | | 67-74: | | | 76.5%
Marentette, Gerth, Billings, et al., 2002 #1598 | | | | | | | 75-95: | | | 77.0%
Marentette, Gerth, Billings, et al., 2002 #1598 | | | | | | | Note: “Persistence” includes combinations and switches; in essence, what is being modeled is failure to discontinue. 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Matsuda, Hayashi, and Saruta, 2003 #1599 | Geographical location: Honjo, Ashikaga, Tochigi, Japan Study dates: 1998-1999 Funding source: NR Interventions:; - ACE group - perindopril 2 mg or trandolapril 1 mg (dose titrated to achieve SBP < 135 and DBP < 85) (n = 27); - ARB group – losartan 25 mg or candesartan 4 mg (dose titrated to achieve SBP < 135 and DBP < 85) (n = 25); Study design: RCT, parallel-group Blinding:; - Patients: NR; - Providers: NR; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: NR Duration of treatment: 48 weeks Duration of post-treatment followup: NR | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 52; - Began treatment: 52; - Completed treatment: 52; - Withdrawals/losses to followup: 0; Age: Mean (SD): 52 Median: NR Range: NR Sex (n [%]): Female: 23 (44%) Male: 29 (56%) Race/ethnicity (n [%]): NR Baseline blood pressure: Average of 2 measurements taken after 5 min in sedentary position (seated or supine NR) | | | | | 1) Blood pressure: | | | | | | General comments:; - All data were presented to compare subgroups with mild and moderate proteinuria with regard to effect of ACEI versus ARB; Quality assessment: Overall rating: Poor Comments:; - Poorly described methods regarding washout, co-interventions, dose titration; - Position of BP measurement not described; - No data on safety/adverse events; Applicability:; - Patient ethnicity not described, but likely all Japanese
Matsuda, Hayashi, and Saruta, 2003 #1599 | | | | | | | | | Mild proteinuria | | Mod proteinuria
Matsuda, Hayashi, and Saruta, 2003 #1599 | | | | | | | SBP | | ACE | | ARB
Matsuda, Hayashi, and Saruta, 2003 #1599
Matsuda, Hayashi, and Saruta, 2003 #1599 | | | | | | | Baseline | | 148±3 | 154±4 | 152±4 | 150±3
Matsuda, Hayashi, and Saruta, 2003 #1599 | | | | | | | 12 wk | | 135±3 | 137±3 | 134±4 | 137±4
Matsuda, Hayashi, and Saruta, 2003 #1599 | | | | | | | 24 wk | | 132±4 | NR | 120±3 | NR
Matsuda, Hayashi, and Saruta, 2003 #1599 | | | | | | | 48 wk | | 131±4 | NR | 124±3 | NR
Matsuda, Hayashi, and Saruta, 2003 #1599 | | | Mild proteinuria | | Mod proteinuria | | | | Mild proteinuria | | Mod proteinuria
Matsuda, Hayashi, and Saruta, 2003 #1599 | | | ACE n = 13 | ARB n =13 | ACE n = 14 | ARB n = 12 | DBP | | ACE | ARB | ACE | ARB
Matsuda, Hayashi, and Saruta, 2003 #1599
Matsuda, Hayashi, and Saruta, 2003 #1599 | | S | 148 ± 3 | 154 ± 4 | 152 ± 4 | 150 ±3 | Baseline | | 86±5 | 86±3 | 90±3 | 89±3
Matsuda, Hayashi, and Saruta, 2003 #1599 | | D | 86 ± 5 | 86 ± 3 | 90 ± 3 | 89 ± 3 | 12 wk | | 76±4 | 71±2 | 78±3 | 79±3
Matsuda, Hayashi, and Saruta, 2003 #1599 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: Outpatient clinic Inclusion criteria:; - Hypertension (SBP > 140 and/or DBP > 90 mmHg); - Proteinuria (> 0.3 g/24 hr); - Serum creatinine level < 265 μmol/L or creatinine clearance > 30 mL/min/1.72 m^2^; Exclusion criteria:; - Diabetic nephropathy; - Polycystic kidney disease; - Chronic pyelonephritis | | | | | 24 wk | | 80±3 | NR | NR | NR
Matsuda, Hayashi, and Saruta, 2003 #1599 | | | | | | | 48 wk | | 74±4 | NR | NR | NR
Matsuda, Hayashi, and Saruta, 2003 #1599 | | | | | | | 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: “Neither ACE-I nor ARB had any effect on creatinine clearance” 13) Proteinuria: No change in patients with mild proteinuria. In patients with moderate proteinuria, ACEI reduced proteinuria by 44 ± 6% (from 2.7 ± 0.5 to 1.5 ± 0.4 g/d; p < 0.05, n = 14) at 12 wks and 54 ± 7% at 48 wk (1.2 ± 0.2 g/d) ARB caused a 23 ± 8% decrease (from 2.7 ± 0.4 to 2.0 ± 0.4 g/d, p > 0.2, n = 12) at 12 wk (p < 0.05 versus ACEI) and 41% at 48 wk (p > 0.5 versus ACEI)

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Mazzaglia, Mantovani, Sturken-boom, et al., 2005 #1600 | Geographical location: Italy Study dates: 2000-2001 Funding source: Pfizer Italia Interventions: A single antihypertensive in one of the following classes:; - α-blockers (n = 662); - Diuretics (n = 2177); - β-blockers (n = 1780); - Calcium channel blockers (CCBs, n = 2700); - ACE inhibitors (n = 4602); - ARBs (n = 1382); Study design: Retrospective cohort study Blinding: NA Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: 365 days Duration of post-treatment followup: NA | Number of patients: Of 409,724 in the Health Search Database, 24,540 were newly diagnosed with hypertension; of these, 13,303 satisfied inclusion criteria (4967 did not receive antihypertensive therapy within 90 days of diagnosis, 6270 were started on combination therapy) Age (ACEI/ARB): Mean (SD): 66.0 (12.8)/64.0 (12.6) Median: NR Range: NR Sex (ACEI/ARB; n [%]): Female: 2484 (54.0%)/770 (55.7%) Male: 2118 (46.0%)/612 (44.3%) Race/ethnicity (n [%]): NR Baseline blood pressure: Average of last 2 separate measurements made by physicians within 3 mo before index date; method of assessment not specified | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: See below, under Persistence/adherence 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: Patients classified into one of the following groups: [underlined: Continuers]: Patients continuing the first-line medication for at least 1 yr; [underlined: Combiners]: Patients receiving an additional type of antihypertensive drug and continuing the initial medication; [underlined: Switchers]: Patients changing from the first-line to another antihypertensive class and discontinuing the initial treatment; [underlined: Discontinuers]: Patients stopping the first-line therapy without having another antihypertensive prescription during followup. | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments:; - Cohort study, requiring multivariate adjustment to make groups more comparable; Applicability:; - Reflects Italian practice patterns and study population
Mazzaglia, Mantovani, Sturken-boom, et al., 2005 #1600 | | | [underlined: ACEI] | | [underlined: ARB]
Mazzaglia, Mantovani, Sturken-boom, et al., 2005 #1600 | | SBP | 153.1 ± 19.1 | | 153.2 ± 18.6 | | | | ACEI | | ARB
Mazzaglia, Mantovani, Sturken-boom, et al., 2005 #1600 | | DBP | 90.1 ± 10.6 | | 90.6 ± 10.2
Mazzaglia, Mantovani, Sturken-boom, et al., 2005 #1600 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): | | | | | Continuers | | 23.3% | | 25.2%
Mazzaglia, Mantovani, Sturken-boom, et al., 2005 #1600 | | | [underlined: ACE] | | [underlined: ARB]
Mazzaglia, Mantovani, Sturken-boom, et al., 2005 #1600 | | CAD | 179 (3.9) | | 54 (4.0) | | Combiners | | 26%^*^ | | 25%^*^
Mazzaglia, Mantovani, Sturken-boom, et al., 2005 #1600 | | HF | 45 (0.98) | | 14 (1.01)
Mazzaglia, Mantovani, Sturken-boom, et al., 2005 #1600 | | DM | 564 (12.3) | | 101 (7.3) | | Switchers | | 10%^*^ | | 8%^*^
Mazzaglia, Mantovani, Sturken-boom, et al., 2005 #1600 | | Stroke | 141 (3.1) | | 43 (3.1)
Mazzaglia, Mantovani, Sturken-boom, et al., 2005 #1600 | | Dyslip | 415 (9.0) | | 220 (8.7) | | Discontinuers | | 40%^*^ | | 42^*^
Mazzaglia, Mantovani, Sturken-boom, et al., 2005 #1600 | | COPD | 244 (5.3) | | 85 (6.2)
Mazzaglia, Mantovani, Sturken-boom, et al., 2005 #1600 | | Prostate | 218 (4.7) | | 53 (3.8) | | ^*^Estimates based on Figure 1; values not reported in text or tables Adjusted hazard ratio for discontinuation = 0.5 (95% CI 0.47 to 0.54) for ACEI, and 0.44 (0.41 to 0.48) for ARB. Adjusted hazard ratio for combining = 1.45 (1.29 to 1.64) for ACEI, and 1.35 (1.16 to 1.57) for ARB. (Adjustment included age, sex, baseline BP, comorbidities, and family history) 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Mazzaglia, Mantovani, Sturken-boom, et al., 2005 #1600 | | 2+ comorbidities | 479 (10.4) | | 129 (9.3)
Mazzaglia, Mantovani, Sturken-boom, et al., 2005 #1600 | | Recruitment setting: Primary care clinics engaged in the Health Search Database Inclusion criteria:; - Newly diagnosed hypertensives (ICD-9: 401-404, 437.2); - Age ≥ 35 yr during 2000-1; - Registered with one of the participating GPs for at least 1 yr before entry into the study; - Received at least one antihypertensive medication within 3 mo of diagnosis; Exclusion criteria:; - Received antihypertensive drugs within 6 months prior to index date; - Less than 365 days of valid follow-up after entry to the cohort; - Received one-pill combination therapy or multiple pill medications as first-line therapy

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
McInnes, O'Kane, Istad, et al., 2000 #1601 | Geographical location: Multicenter: Glasgow, UK; Oslo, Norway; Oula, Finland; Oude Wetering, The Netherlands Study dates: NR Funding source: Astra Hassle Interventions:; - Candesartan cilexetil 8 mg + HCTZ 12.5 mg (n = 237); - Lisinopril 10 mg + HCTZ 12.5 mg (n = 116); No dose titration; no co-interventions Study design: RCT, parallel-group Blinding:; - Patients: Yes (double-dummy); - Providers: Yes; - Assessors of outcomes: Yes; Was allocation concealment adequate?: Yes (although blocks of 3 were used, central randomization should have controlled for this) Baseline/run-in period: NR Duration of treatment: 26-30 wk; outcomes reported at 26 wk Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: 418; - Randomized: 355; - Began treatment: 353; - Completed treatment: 286; - Withdrawals/losses to followup: 67; Age: Mean (SD): 57.5 ± 9.7 Median: NR Range: NR Sex (n [%]): Female: 158 (45%) Male: 195 (55%) Race/ethnicity (n [%]): Caucasian: 348 (99%) Baseline blood pressure: Seated trough BP assessed using a fully automated device (Omron HEM-705CP). Mean of 3 measurements taken at 2-min intervals after patient seated for 5 min. | | | | | 1) Blood pressure: Results for ITT population (n = 237 candesartan, 116 lisinopril) Seated BP at 26 weeks: | | | | | | General comments:; - Patients withdrawn if mean sitting BP > 180/100 at 2 visits 2-4 weeks apart, resulting in high level of withdrawal prior to 26-wk endpoint; Quality assessment: Overall rating: Fair Comments:; - Not clear if there was a run-in period (mentioned in results, but not methods); - Because no clear run-in, comparison is of patients' prior BP treatment and treatment with study drug; since prior treatment varied, significance of change observed is unclear; would have been better to have placebo run-in to get baseline BP or at least to group results by prior drug type; - Difficult to tell how many patients withdrew and the reasons for withdrawal; - Very little baseline information about the patients; Applicability:; - Racially homogenous – all white northern European patients; - Recruitment setting not described; - Low dose of lisinopril used
McInnes, O'Kane, Istad, et al., 2000 #1601 | | | | | | | | | Candesartan/HCTZ | | Lisinopril/HCTZ
McInnes, O'Kane, Istad, et al., 2000 #1601
McInnes, O'Kane, Istad, et al., 2000 #1601 | | | | | | | SBP | | 151.1± 19.1 | | 145.9 ± 18.4
McInnes, O'Kane, Istad, et al., 2000 #1601 | | | | | | | DBP | | 93.0 ± 9.3 | | 91.2 ± 8.4
McInnes, O'Kane, Istad, et al., 2000 #1601 | | | | | | | Direct statistical testing NR; analyses of adjusted mean change results have p-values > 0.05. Response rates at 26 wk (seated DBP ≤ 90 mm Hg and/or reduction of ≥ 10 mm Hg from baseline): Candesartan/HCTZ: 129/237 (54.4%) Lisinopril/HCTZ: 72/116 (62.1%) p = 0.094 Other outcomes reported: BP control rates (seated DBP ≤ 90 mm Hg) Mean seated BP at 2 and 12 wk (Figure 1) Standing BP outcomes Some outcomes also reported for per-protocol population 2) Rate of use of a single antihypertensive agent for BP control: Study drugs both combination agents; no other antihypertensives medications allowed 3) Mortality: NR 4) Morbidity: NR 5) Safety:
McInnes, O'Kane, Istad, et al., 2000 #1601 | | | Candesartan/HCTZ | | Lisinopril/HCTZ | | | | [underlined: Lisinopril] | | [underlined: Candesartan]
McInnes, O'Kane, Istad, et al., 2000 #1601 | | | | | | | Pts with AEs | | 93 (79.5%) | | 164 (68.9%)
McInnes, O'Kane, Istad, et al., 2000 #1601 | | SBP: | 169.2 ± 17.2 | | 163.3 ± 16.9 | | Atrributable AEs | | 80 (33.6%) | | 54 (46.2%)
McInnes, O'Kane, Istad, et al., 2000 #1601 | | DBP | 102.9 ± 5.5 | | 101.8 ± 4.9 | | Withdrawn d/t AE | | 14 (5.9%) | | 14 (12.0%)
McInnes, O'Kane, Istad, et al., 2000 #1601 | | Concurrent medications (n [%]): No other antihypertensives allowed Comorbidities (n [%]): NR (patients reported to be similar across groups in race, height, BMI, medical history, duration of hypertension, and WHO stage.) Recruitment setting: NR Inclusion criteria:; - Age 20-80 yr; - Primary HTN; - Diastolic BP 95-115 on 2 occasions 1-2 wk apart, 24 hr after antihypertensive monotherapy; Exclusion criteria:; - Women of child-bearing potential; - Recent significant CV event or condition; - Concomitant drugs with BP modulating effects; - Contraindications to any of study drugs; - Severe concomitant disease; - Conditions associated with poor compliance
McInnes, O'Kane, Istad, et al., 2000 #1601 | | | | | | | 2 cases of angioedema were reported in the lisinopril group (2/116 = 1.7%) vs. none in the candesartan group 6) Specific adverse events:
McInnes, O'Kane, Istad, et al., 2000 #1601 | | | | | | | | | [underlined: Lisinopril] | | [underlined: Candesartan]
McInnes, O'Kane, Istad, et al., 2000 #1601 | | | | | | | Dizziness/vertigo | | 11.8% | | 15.4%
McInnes, O'Kane, Istad, et al., 2000 #1601 | | | | | | | Headache | | 11.8% | | 8.5%
McInnes, O'Kane, Istad, et al., 2000 #1601 | | | | | | | Viral infection | | 8.8% | | 7.7%
McInnes, O'Kane, Istad, et al., 2000 #1601 | | | | | | | Fatigue | | 5.9% | | 6.0
McInnes, O'Kane, Istad, et al., 2000 #1601 | | | | | | | Back pain | | 5.5% | | 5.1%
McInnes, O'Kane, Istad, et al., 2000 #1601 | | | | | | | Resp infection | | 5.5% | | 9.4%
McInnes, O'Kane, Istad, et al., 2000 #1601 | | | | | | | Pain | | 5.0% | | NR
McInnes, O'Kane, Istad, et al., 2000 #1601 | | | | | | | Cough | | 4.6% | | 23.1%
McInnes, O'Kane, Istad, et al., 2000 #1601 | | | | | | | Myalgia | | 4.2% | | 6.0%
McInnes, O'Kane, Istad, et al., 2000 #1601 | | | | | | | Nausea | | 4.2% | | NR
McInnes, O'Kane, Istad, et al., 2000 #1601 | | | | | | | Accident/injury | | NR | | 4.3%
McInnes, O'Kane, Istad, et al., 2000 #1601 | | | | | | | Pharyngitis | | NR | | 4.3%
McInnes, O'Kane, Istad, et al., 2000 #1601 | | | | | | | 7) Persistence/adherence: As assessed by tablet count, 90% of patients took 90-110% of study medications – similar in two treatment groups 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Menne, Farsang, Deak, et al., 2008 #327 | Geographical location: 24 primary and hospital centers in Hungary & Germany Study dates: Aug 2004 – May 2007 Funding source: Novartis Pharma GmbH Interventions:; - Valsartan 320 mg (n = 43); - Lisinopril 40 mg (n = 47); - Valsartan 320 mg/lisinopril 20 mg (n = 43); Titration in 3 steps over 6 weeks: Valsartan 80-320 mg Lisinopril 10-40 mg Valsartan/Lisinopril 80/10 – 320/20 Were additional anti-hypertension medications allowed: Yes If Yes to above, was this done: Per protocol Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: Yes; Was allocation concealment adequate?: Yes Baseline/run-in period: No meds for 2 weeks, then single-blind placebo for 1 week Duration of treatment: 30 weeks Duration of post-treatment followup: NR | Number of patients: N = 133; - Screened for inclusion: 331; - Eligible for inclusion: NR; - Randomized: 133; - Began treatment: 133; - Completed treatment: 115; - Withdrawals/losses to followup: 18 (129 were analyzed: 4 were not included in analyses b/c no measurements after 12 wks); Age: Mean (SD): 58.6 ±10.8 Sex (n [%]): Female: 37 (28.7%) Male: 92 (71.3%) Race/ethnicity (n [%]): NR Baseline blood pressure: Mean (± SD): | | | | | 1) Blood pressure: Reduction in seated trough BP – 12 weeks: | | | | | | General comments:; - Limited to patients with microalbuminuria; - Missing data were imputed by last observation carried forward, which can introduce bias; Quality assessment: Overall rating: Good Comments:; - Adequate randomization, blinding; - Patients comparable at baseline and treated similarly during study; Applicability:; - Non-US setting; - Limited to patients with HTN and microalbuminuria
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | | | | | | | | SBP | | DBP
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | | | | | | Lisinopril | | 14.1 | | 10.0
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | | | | | | Valsartan | | 16.0 | | 11.8
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | | | | | | Combo | | 16.9 | | 11.5
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | | | | | | Reduction in seated trough BP – 30 weeks:
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | | SBP | | DBP | | | | SBP | | DBP
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | Lisinopril | 153.0 ± 14.3 | | 90.6 ± 8.3 | | Lisinopril | | 14.0 | | 11.1
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | Valsartan | 153.1 ± 16.0 | | 91.9 ± 7.7 | | Valsartan | | 16.0 | | 10.9
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | Combo | 150.4 ± 13.7 | | 90.1 ± 8.4 | | Combo | | 16.4 | | 11.5
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | Concurrent non-hypertension medications (%): | | | | | No statistical differences % patients with normal BP at 30 weeks:
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | | | L | V | V/L | | | | L | V | V/L
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | HCTZ | | 19.1 | 23.3 | 11.6 | % | | | 25.5 | 26.2 | 30.0
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | Amlodipine | | 19.1 | 9.3 | 11.6 | P = 0.034 for between-groups comparison 2) Rate of use of a single antihypertensive agent for BP control: Lisinopril: 32% Valsartan: 39.5% Valsartan/lisinopril: 46.6% 3) Mortality: 1 death each in lisinopril and combination arms 4) Morbidity: NR 5) Safety:
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | Both | | 29.8 | 27.9 | 30.2
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | HTN medication at baseline (%):
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | | | L | V | V/L
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | ACEI | | 59.6 | 51.1 | 53.5
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | ARB | | 23.4 | 11.7 | 9.4 | | | | All AE N (%) | AE with d/c | AE due to drug
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | CCB | | 19.1 | 16.3 | 23.3 | Lisinopril | | | 29 (61.7) | 4 (8.5) | 6 (12.8)
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | BB | | 38.1 | 27.9 | 32.5 | Valsartan | | | 27 (62.8) | 3 (7.0) | 8 (18.6)
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | Diuretic | | 19.3 | 16.3 | 11.7 | Combo | | | 31 (72.1) | 3 (7.0) | 11 (25.6)
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | Comorbidities (%): | | | | | 6) Specific adverse events:
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | | | L | V | V/L | | | | L | V | V/L
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | Cardiac d/o | | 25.5 | 11.6 | 18.6 | Hyper-kalemia | | | 10.6% | 11.6% | 18.6%
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | Type 2 DM | | 74.5 | 74.4 | 76.7 | Cough | | | 4.3% | 0 | 2.3%
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | Hyper-lipidemia | | 51.1 | 41.9 | 34.9 | Hypo-tension | | | 4.3% | 9.3% | 11.6%
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | Recruitment setting: Primary and hospital centers in Hungary and Germany Inclusion criteria:; - Age 18-75; - Essential HTN defied as mean sitting DBP 85-110 mmHg; - Microalbuminuria (women 3.5-35 mg/mmol, men 2.5-25 mg/mmol); Exclusion criteria:; - Primary kidney disease; - Renal impairment (CrCL < 30 ml/min); - Heart failure; - Significant arrythymia/bradycardia; - Relevant valvular disease; - Type 1 DM; - Uncontrolled Type 2 DM (Hgba1c > 8%); - History of MI, PTCA, CABG, CVA in past 12 months; - Unstable angina; - Renal transplantation; - Severe hepatic disease/failure; - Malignancy or history of malignancy in past 5 yrs; - Systemic inflammatory disease; - Pregnant or breastfeeding; - Psychiatric disease; - Alcohol or drug abuse
Menne, Farsang, Deak, et al., 2008 #327 | | | | | | | (Hyperkalemia data taken from text, pg 1864, not Table 3) 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: UACR (mg/mmol)
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | | | | | | | | Baseline | | 30 weeks
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | | | | | | Lisinopril | | 9.6 | | 5.7
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | | | | | | Valsartan | | 9.1 | | 4.5
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | | | | | | Combo | | 9.5 | | 3.6
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | | | | | | Difference between ACEI and ARB nonsignificant Combo better than lisinopril (p = 0.029) % patients with resolution of microalbuminuria at 30 weeks
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | | | | | | | | | L | V | V/L
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | | | | | | % | | | 17 | 31 | 38
Menne, Farsang, Deak, et al., 2008 #327
Menne, Farsang, Deak, et al., 2008 #327 | | | | | | | P = 0.034 for between-groups comparison

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Mimran, Ruilope, Kerwin, et al., 1998 #1602 | Geographical location: Multicenter trial (France??, Spain??) Study dates: NR Funding source: Bristol-Myers Squibb/Sanofi Interventions:; - Irbesartan 75 mg (n = 98); - Enalapril 10 mg (n = 102); One capsule once a day between 6 and 10 a.m. If DBP at trough was ≥ 90 mm at weeks 4 or 8, dosage was doubled (irbesartan increased from 150 mg, enalapril to 20 mg). If SBP remained ≥ 90 mm at week 8 doses doubled again (300 mg and 40 mg). Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: 4-to 5-wk single-blind placebo lead-in period Duration of treatment: 12 weeks Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion:; - Eligible for inclusion:; - Randomized: 200; - Began treatment: 200; - Completed treatment: 191; - Withdrawals/losses to followup: 9, 4 due to AEs, 3 at patient request, 2 lost to followup; Age: Mean (SD): 58.3 Median: NR Range: 145 < 65 yr; 55 ≥ 65 yr; 15 ≥ 75yr Sex (n [%]): Female: 99 Male: 101 Race/ethnicity (n [%]): NR Baseline blood pressure: Measured by a standard calibrated mercury sphygmomanometer. Mean of 3 readings take 1 min apart used. Seated and standing readings taken. Baseline seated BP: | | | | | 1) Blood pressure: Numerical results not reported. Both groups: Statistically significant decreases from baseline trough SBP and DBP at all measured time points (weeks 2-12). No statistically significant difference between regimes with respect to decrease in SBP or DBP. Results consistent across both sexes and all age groups. Pts maintained on lowest doses: DBP decreased by 15 mm within 4 weeks with no further decreases. Patients whose dose was doubled once: Mean DBP decreased by 8 mm with lowest doses, but mean DBP was above 90 mm. Doubling was associated with additional decrease of 5 mm between wks 4 and 8 for both groups, resulting in a decrease from baseline of 13 mm with little change thereafter. Patients whose dose was doubled twice: DBP decreased by 5 mm and 1 mm in both groups, resulting in a total decrease from baseline of 11 mm and 8 mm in enalapril and irbesartan groups. At 12 wks:; - Mean DBP was higher in those titrated than those maintained at lowest dosages.; - 66% of irbesartan and 63% of enalapril group were normalized (DBP < 90mm).; 2) Rate of use of a single antihypertensive agent for BP control (different doses): NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: (see next page) | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #1602 | | | [underlined: Enalapril] | | [underlined: Irbesartan] | | | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #1602 | | SBP: | 164.9 ± 12.8 | | 163.9 ± 12.5 | | | | Enalapril (%) (n = 102) | | Irbesartan (%) (n = 98) | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #1602 | | DBP: | 101.8 ± 4.2 | | 101.0 ± 4.1 | | | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #1602 | | Concurrent medications (n [%]): NR (though see Exclusion criteria) Comorbidities (n [%]): NR (though see Exclusion criteria) Recruitment setting: NR Inclusion criteria:; - Lead-in medication consumption > 80% and < 120%; - DBP on days 22-29 (or days 29 and 36) between 95 mm Hg and 110 mm Hg inclusive, values on each day not differing by more than 8 mm Hg; - Age ≥ 18 yr; Exclusion criteria:; - Concomitant diseases or medications that would present a safety hazard or interfere with assessment of safety or efficacy of study medications; - Women who were pregnant, lactating, or of child-bearing potential | | | | | Adverse drug experience | | 26 | | 19 | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #1602 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #1602 | | | | | | | AE | | 43 | | 45 | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #1602 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #1602 | | | | | | | Serious AE | | 1.0 | | 4.1 | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #1602 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #1602 | | | | | | | Discontinued | | 2.9 | | 1.0 | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #1602 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #1602 | | | | | | | 6) Specific adverse events: Patients with cough (%): Enalapril: 15% Irbesartan: 7% 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: Mean change in lab parameters at week 12 (95% CI): | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #1602 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #1602 | | | | | | | | | Enalapril n = 96 | | Irbesartan n = 94 | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #1602 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #1602 | | | | | | | Creatinine (mg/dL) | | 0.03 (0 to 0.06) | | 0.01 (-0.02 to 0.04) | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #1602 | | | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned
Mimran, Ruilope, Kerwin, et al., 1998 #1602 | | | | | | | 13) Proteinuria: NR | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments: No description of sites, or criteria for selection of sites Applicability: Race of patients not mentioned

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Mogensen, Neldam, Tikkanen, et al., 2000 #1603 | Geographical location: 37 sites in Australia, Denmark, Finland, and Israel Study dates: NR Funding source: AstraZeneca Interventions: Randomized to 1 of 4 groups by treatment in 2 × 12-week periods:; - Candesartan/candesartan (n = 66); - Lisinopril/lisinopril (n = 64); - Candesartan/candesartan + lisinopril (n = 34); - Lisinopril/candesartan + lisinopril (n = 35); Doses were: candesartan 16 mg, lisinopril 20 mg Co-interventions: Some patients also received HCTZ 12.5, but protocol for giving this not described Study design: RCT, parallel-group (performed as a mixed study; analyzed as a parallel-group study) Blinding:; - Patients: Yes (double-dummy); - Providers: Yes; - Assessors of outcomes: Yes; Was allocation concealment adequate?: NR Baseline/run-in period: 4-wk placebo run-in Duration of treatment: 24 wk Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 199; - Began treatment: 198; - Completed treatment: NR; - Withdrawals/losses to followup: 2 excluded from 12- and 24-wk analyses (1 never took study med, 1 provided no efficacy data); additional 53 excluded from 24-wk analysis (“most because their DBP was below 80 mm Hg”); Age: Mean (SD): 59.8 Median: NR Range: NR Sex (n [%]): Candesartan/lisinopril: Female: 99 (50%) Male: 98 (50%) Race/ethnicity (n [%]): NR Baseline blood pressure: Seated trough BP measured after 5-min rest using automatic device (Omron HEM-705 CP). Mean of 3 measures separated by 2 min analyzed. | | | | | 1) Blood pressure: Mean post-treatment BP values NR (except in Figure 2) Mean reduction (95% CI) in seated trough BP at 12 wk: | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments:; - Primary results (mean post-treatment values) NR; report only differences from baseline; - 24-wk results not analyzed for candesartan vs. lisinopril, only the combination vs. each individual; - Addition of HCTZ permitted, but protocol for this not described; Applicability:; - All patients had type 2 diabetes and microalbuminuria; - Recruitment not described
Mogensen, Neldam, Tikkanen, et al., 2000 #1603
Mogensen, Neldam, Tikkanen, et al., 2000 #1603 | | | | | | | | Candesartan (n = 99) | Lisinopril (n = 98) | | Adjusted^*^ mean diff. between groups
Mogensen, Neldam, Tikkanen, et al., 2000 #1603
Mogensen, Neldam, Tikkanen, et al., 2000 #1603 | | | | | | | SBP | 12.4 (9.1 to 15.8) | 15.7 (12.2 to 19.2)^*^ | | 3.3 (-1.5 to 8.2) p = 0.18
Mogensen, Neldam, Tikkanen, et al., 2000 #1603
Mogensen, Neldam, Tikkanen, et al., 2000 #1603 | | | | | | | DBP | 9.5 (7.7 to 11.2) | 9.7 (7.9 to 11.5) | | 0.02 (-2.3 to 2.7) p > 0.20
Mogensen, Neldam, Tikkanen, et al., 2000 #1603
Mogensen, Neldam, Tikkanen, et al., 2000 #1603 | | | | | | | ^*^Adjusted for center, treatment, baseline value, weight, and change in DBP Mean reduction (95% CI) in seated trough BP at 24 wk:
Mogensen, Neldam, Tikkanen, et al., 2000 #1603
Mogensen, Neldam, Tikkanen, et al., 2000 #1603 | | | | | | | | | Candesartan (n = 49) | | Lisinopril (n = 46)
Mogensen, Neldam, Tikkanen, et al., 2000 #1603
Mogensen, Neldam, Tikkanen, et al., 2000 #1603 | | | | | | | SBP | | 14.1 (8.9 to 19.2) | | 16.7 (11.4 to 21.9)
Mogensen, Neldam, Tikkanen, et al., 2000 #1603
Mogensen, Neldam, Tikkanen, et al., 2000 #1603 | | | | | | | DBP | | 10.4 (7.7 to 13.1) | | 10.7 (8.0 to 13.5)
Mogensen, Neldam, Tikkanen, et al., 2000 #1603
Mogensen, Neldam, Tikkanen, et al., 2000 #1603 | | | | | | | No statistical tests reported for comparison between candesartan and lisinopril monotherapies at 24 wk 2) Rate of use of a single antihypertensive agent for BP control: Number of patients given HCTZ in addition to study drugs at 12 wk: Candesartan: 18/99 (18%) Lisinopril: 27/98 (28%) Number of patients given HCTZ in addition to study drugs at 24 wk: Candesartan: 7/49 (14%) Lisinopril: 6/46 (13%) 3) Mortality: NR 4) Morbidity: NR 5) Safety: 14/197 stopped treatment due to AEs: 5 due to dizziness, weakness, or both (candesartan 2, lisinopril 2, combination 1); 3 due to cough (all lisniopril). Others not specified. 6) Specific adverse events: NR except AEs leading to withdrawal (see immediately above) 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: No clear changes in mean values for HbA1c from baseline to 12 or 24 wk in any of the treatment groups (no quantitative data reported) 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: Mean post-treatment urinary albumin:creatinine ratios NR Mean reduction in urinary albumin:creatinine ratio (%, with 95% CI) at 12 wk:
Mogensen, Neldam, Tikkanen, et al., 2000 #1603 | | | Candesartan (n = 99) | | Lisinopril (n = 98)
Mogensen, Neldam, Tikkanen, et al., 2000 #1603
Mogensen, Neldam, Tikkanen, et al., 2000 #1603 | | SBP | 162.7 ± 17.7 | | 162.6 ± 17.6
Mogensen, Neldam, Tikkanen, et al., 2000 #1603 | | DBP | 96.0 ± 6.2 | | 95.7 ± 6.2
Mogensen, Neldam, Tikkanen, et al., 2000 #1603 | | Concurrent medications (n [%]): Oral anti-diabetic drugs: “about 80%” of patients in both groups Insulin: 20% in both groups Comorbidities (n [%]): All patients with hypertension, diabetes type 2 and microalbuminuria Recruitment setting: Tertiary hospitals and primary care clinics Inclusion criteria:; - Age 30-74 yr; - Type 2 diabetes; - Urinary albumin:creatinine ratio 2.5-25 mg/mmol, diastolic BP 90-110 mmHg after 2 and 4 wk of placebo, respectively; Exclusion criteria:; - BMI ≥ 40 kg/m^2^; - SBP > 200 mm Hg; - Non-diabetic cause of secondary hypertension; - Cardiovascular event < 6 mo; - Serum creatinine ≥ 130 ×6d mol/L in women and ≥ 150 × 6d ml/L in men; - Serum potassium > 5.5 mmol/L; - HbA1c > 10%; - Pregnancy or potential pregnancy or breastfeeding
Mogensen, Neldam, Tikkanen, et al., 2000 #1603
Mogensen, Neldam, Tikkanen, et al., 2000 #1603 | | | | | | | Candesartan (n = 99) | | Lisinopril (n = 98) | | Adjusted^*^ mean diff. between treatments
Mogensen, Neldam, Tikkanen, et al., 2000 #1603
Mogensen, Neldam, Tikkanen, et al., 2000 #1603 | | | | | | | 30 (15 to 42) | | 46 (35 to 56) | | 30 (1 to 71) p = 0.58
Mogensen, Neldam, Tikkanen, et al., 2000 #1603
Mogensen, Neldam, Tikkanen, et al., 2000 #1603 | | | | | | | ^*^Adjusted for center, treatment, baseline value, weight, and change in DBP Mean reduction in urinary albumin:creatinine ratio (%, with 95% CI) at 24 wk:
Mogensen, Neldam, Tikkanen, et al., 2000 #1603
Mogensen, Neldam, Tikkanen, et al., 2000 #1603 | | | | | | | Candesartan (n = 49) | | Lisinopril (n = 46) | | Adjusted^*^ mean diff. between treatments
Mogensen, Neldam, Tikkanen, et al., 2000 #1603
Mogensen, Neldam, Tikkanen, et al., 2000 #1603 | | | | | | | 24 (0 to 43) | | 39 (20 to 54) | | Not reported
Mogensen, Neldam, Tikkanen, et al., 2000 #1603
Mogensen, Neldam, Tikkanen, et al., 2000 #1603 | | | | | | | ^*^Adjusted for center, treatment, baseline value, weight, and change in DBP

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Naidoo, Sareli, Marin, et al., 1999 #1604 | Geographical location: 21 centers in South Africa, Hungary, Czech Republic, Slovak Republic, Argentina, Brazil, and Colombia Study dates: NR Funding source: Merck Interventions:; - Losartan 100 mg + HCTZ 25 mg (n =176); - Enalapril 10 mg ± HCTZ 25 mg (n =173); Dose titration and co-interventions: Beginning at wk 2, amlodipine 5 mg could be added if DBP > 105, with titration to 10 mg if DBP > 90 at next visit Patients with inadequate BP control (SBP > 220 and/or DBP > 120 or increased > 15 from baseline) at 2 successive measurements at least 3 days apart were discontinued from the trial Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: Yes; Was allocation concealment adequate?: NR Baseline/run-in period: 2 days no meds Duration of treatment: 12 wk Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 349; - Began treatment: 325; - Completed treatment: 311; - Withdrawals/losses to followup: 38, some before and some after starting treatment (12 due to AEs, 12 due to protocol violations, 7 lost to followup, 5 lack of cooperation, 2 insufficient response); Age: Mean (SD): 53.25 Median: NR Range: NR Sex (n [%]): Female: 201 (58%) Male: 148 (42%) Race/ethnicity (n [%]): Caucasian: 174 (50%) Black: 98 (28%) Other: 77 (22%) Baseline blood pressure: Seated trough BP measured 3 times after a 5-min rest using a standard mercury sphygmomanometer; average of 3 readings used | | | | | 1) Blood pressure: Mean BP at 12 wk (entire sample): | | | | | | General comments:; - Patients with inadequate BP control (SBP > 220 and/or DBP > 120 or increased > 15 from baseline) at 2 successive measurements at least 3 days apart were discontinued from the trial; Quality assessment: Overall rating: Fair Comments:; - Varying numbers of patients reported in text and tables; - 12-wk outcomes compared with prestudy treatment in primary statistical analysis; Applicability:; - Recruitment setting not described; - Extensive exclusion criteria
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | | | Losartan/HCTZ [underlined: (n = 173)] | | Enalapril/HCTZ [underlined: (n = 173)]
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | SBP | | 139.7 ± 17.6 | | 140.5 ± 15
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | DBP | | 88.7 ± 10.1 | | 88.4 ± 8.3
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | Mean BP for patients not receiving adjunctive amlodipine:
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | | | Losartan/HCTZ [underlined: (n = 129)] | | Enalapril/HCTZ [underlined: (n = 124)]
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | SBP baseline | | 159.8 ± 13.7 | | 161.5 ± 15.1
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | SBP 12 wk | | 137.3 ± 16.6 | | 139.2 ± 14.6
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | DBP baseline | | 103.0 ± 5.8 | | 103.2 ± 7.0
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | DBP 12 wk | | 87.1 ± 10 | | 87.5 ± 8.7
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | Note: Ns reported above are as given in the relevant data tables; varying figures given in text and other tables Authors reported that “both regimens were effective in black (n = 54 losartan/HCTZ; n = 44 enalapril/HCTZ) and non-black patients (data not shown)” BP control rates (control not clearly defined): Losartan/HCTZ: 63% Enalapril/HCTZ: 58.4% 2) Rate of use of a single antihypertensive agent for BP control: NA; all patients taking a combination agent ± additional therapy 3) Mortality: NR 4) Morbidity: NR 5) Safety: No. of patients with ≥ 2 drug-related AEs: Losartan/HCTZ: 29 (16.5%) Enalapril/HCTZ: 37 (21.4%) Withdrawals due to AEs: Losartan/HCTZ: 5 (2.8%) Enalapril/HCTZ: 7 (4.0%) Withdrawals due to drug-related AEs: Losartan/HCTZ: 3 (1.7%) Enalapril/HCTZ: 3 (1.7%) No serious AEs judged to be drug-related 6) Specific adverse events: AEs not necessarily drug-related:
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | Losartan/ HCTZ | | Enalapril/ HCTZ
Naidoo, Sareli, Marin, et al., 1999 #1604
Naidoo, Sareli, Marin, et al., 1999 #1604 | | SBP | 162.9 ± 16.1 | | 163.8 ± 16.1
Naidoo, Sareli, Marin, et al., 1999 #1604 | | DBP | 104.2 ± 6.3 | | 103.6 ± 7.4
Naidoo, Sareli, Marin, et al., 1999 #1604 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria:; - Moderate or severe hypertension (DBP > 105); - Inadequate control on 2 or more agents (DBP > 90); - At least on drug-related symptom that might be alleviated by medication switch; Exclusion criteria:; - On ACEI prior to study start; - Serious AE on ACEI, diuretic, or ARB; - Malignant or secondary hypertension; - SBP > 220; - Significant CV, GI, hepatic, or blood/coagulation disorders; - Unstable diabetes; - Obesity (arm girth > 41 cm); - Potassium < 3.5 or > 5.5 mEq/L; - Serum creatinine > 150 umol/L; - Bun > 12.5 mmol/L; - Alanine or aspartate aminotransferase value > 50% upper limit normal; - Proteinuria or hematuria; - Cancer; - AIDS; - Absence of a kidney; - Alcohol or drug abuse; - Need for treatment with beta-blockers, psychotropics, antidepressants, cimetidine, oral contraceptives, steroids, corticotropin, or lithium
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | | | Losartan/HCTZ[underlined: (n = 173), %] | | Enalapril/HCTZ[underlined: (n = 170), %]
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | Headache | | 19.1 | | 20.6
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | Palpitations | | 15.6 | | 13.5
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | Tired | | 14.5 | | 17.1
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | Dizzy | | 11.0 | | 5.3
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | Nervous | | 12.1 | | 9.4
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | Flushing | | 10.4 | | 6.5
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | Weakness | | 9.2 | | 7.1
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | Swollen ankles | | 5.8 | | 5.3
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | Muscle pain | | 6.4 | | 8.8
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | Cough | | 6.9 | | 16.5^*^
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | Cold hands/feet | | 6.4 | | 7.6
Naidoo, Sareli, Marin, et al., 1999 #1604 | | | | | | | ^*^p = 0.005, enalapril/HCTZ vs. losartan/HCTZ 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Nakamura, Kawachi, Saito, et al., 2009 #19 | Geographical location: Gunma, Japan Study dates: NR Funding source: Ministry of Education, Culture, Sports, Science and Technology of Japan Interventions: Perindopril 2-8 mg (n = 27) Telmisartan 20-80 mg (n = 26) Mean doses at study end: 4.2 ± 0.4 mg/day 44.6 ± 2.3 mg/day Were additional anti-hypertension medications allowed: Yes If Yes to above, was this done: At discretion of clinician/investigator (allowed to keep existing anti-HTN) Study design: RCT, parallel-group Blinding:; - Patients: NR; - Providers: NR; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: None Duration of treatment: 48 weeks Duration of post-treatment followup: NR | Number of patients: N = 53; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 53; - Began treatment: 53; - Completed treatment: 51; - Withdrawals/losses to followup: 2; Age: Mean (SD): 64.8 ±2.5 Range: 33 - 84 Sex (n [%]): Female: 30 (56.6%) Male: 23 (43.4%) Race/ethnicity (n [%]): NR (assume 100% Japanese) Baseline blood pressure: Figure only, appears to be 158/88 for both groups Concurrent non-hypertension medications (n [%]): | | | | | 1) Blood pressure: BP at 48 weeks, mean (SD) | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments:; - No description of blinding, randomization method; - Small sample size (powered for change in aldosterone); - No description of dose escalation; - Low attrition; all participants accounted for at study end; Applicability:; - Non-US setting
Nakamura, Kawachi, Saito, et al., 2009 #19
Nakamura, Kawachi, Saito, et al., 2009 #19 | | | | | | | | | SBP | | DBP
Nakamura, Kawachi, Saito, et al., 2009 #19
Nakamura, Kawachi, Saito, et al., 2009 #19 | | | | | | | Perindopril | | 137.2 (1.9) | | 77.0 (1.9)
Nakamura, Kawachi, Saito, et al., 2009 #19
Nakamura, Kawachi, Saito, et al., 2009 #19 | | | | | | | Telmisartan | | 136.8 (2.6) | | 76.8 (2.3)
Nakamura, Kawachi, Saito, et al., 2009 #19
Nakamura, Kawachi, Saito, et al., 2009 #19 | | | | | | | Between-groups comparison not statistically significant 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: Cough: 2 perindopril group (causing study discontinuation; were not included in analyses) 7) Persistence/adherence: NR 8) Lipid levels: LDL (mg/dL)
Nakamura, Kawachi, Saito, et al., 2009 #19
Nakamura, Kawachi, Saito, et al., 2009 #19 | | | Perind | | Telmis | | | | Perindopril | | Telmisartan
Nakamura, Kawachi, Saito, et al., 2009 #19
Nakamura, Kawachi, Saito, et al., 2009 #19 | | CCB | 13 (48%) | | 14 (54%) | | Baseline | | 119 ± 7 | | 116 ± 5
Nakamura, Kawachi, Saito, et al., 2009 #19
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Diuretic | 5 (19%) | | 4 (15%) | | 24 weeks | | 122 ± 6 | | 117 ± 5
Nakamura, Kawachi, Saito, et al., 2009 #19
Nakamura, Kawachi, Saito, et al., 2009 #19 | | α blocker | 4 (15%) | | 2 (8%) | | 48 weeks | | 122 ± 6 | | 112 ± 8
Nakamura, Kawachi, Saito, et al., 2009 #19
Nakamura, Kawachi, Saito, et al., 2009 #19 | | BB | 6 (22%) | | 8 (31%) | | HDL (mg/dL)
Nakamura, Kawachi, Saito, et al., 2009 #19
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Comorbidities (n [%]): | | | | | | | Perindopril | | Telmisartan
Nakamura, Kawachi, Saito, et al., 2009 #19
Nakamura, Kawachi, Saito, et al., 2009 #19 | | | Perind | | Telmis | | Baseline | | 51.7 ± 2.5 | | 52.5 ± 4.6
Nakamura, Kawachi, Saito, et al., 2009 #19
Nakamura, Kawachi, Saito, et al., 2009 #19 | | DM | 5 (19%) | | 3 (12%) | | 24 weeks | | 52.1 ± 2.1 | | 51.1 ± 4.3
Nakamura, Kawachi, Saito, et al., 2009 #19
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Lipids | 8 (30%) | | 11 (42%) | | 48 weeks | | 54.1 ± 2.5 | | 50.6 ±4.1
Nakamura, Kawachi, Saito, et al., 2009 #19
Nakamura, Kawachi, Saito, et al., 2009 #19 | | CVD | 3 (11%) | | 1 (4%) | | Triglyceride (mg/dL)
Nakamura, Kawachi, Saito, et al., 2009 #19
Nakamura, Kawachi, Saito, et al., 2009 #19 | | CVA | 0 | | 2 (8%) | | | | Perindopril | | Telmisartan
Nakamura, Kawachi, Saito, et al., 2009 #19
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Smoking | 3 (11%) | | 4 (15%) | | Baseline | | 152.7 ± 17.7 | | 163.0 ± 20.6
Nakamura, Kawachi, Saito, et al., 2009 #19
Nakamura, Kawachi, Saito, et al., 2009 #19 | | ETOH | 11 (41%) | | 8 (31%) | | 24 weeks | | 141.1 ± 11.4 | | 174.6 ± 22.9
Nakamura, Kawachi, Saito, et al., 2009 #19
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | 48 weeks | | 133.8 ± 11.8 | | 153.5 ± 18.2
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | Within-group changes from baseline and between-groups comparisons were not statistically significant 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: Plasma glucose (mg/dL)
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | | | Perindopril | | Telmisartan
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | Baseline | | 110 ± 6 | | 113 ± 4
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | 24 weeks | | 118 ± 7 | | 113 ± 7
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | 48 weeks | | 104 ± 4 | | 112 ± 7
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | HbA1c (%)
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | | | Perindopril | | Telmisartan
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | Baseline | | 5.5 ± 0.2 | | 5.6 ± 0.3
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | 24 weeks | | 5.5 ± 0.1 | | 5.6 ± 0.3
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | 48 weeks | | 5.6 ± 0.2 | | 5.7 ± 0.3
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | Between-groups comparison not statistically significant 11) LV mass/function: NR 12) Creatinine/GFR: Serum creatinine
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | | | Perindopril | | Telmisartan
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | Baseline | | 0.77 ± 0.03 | | 0.73 ± 0.05
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | 24 weeks | | 0.79 ± 0.04 | | 0.79 ± 0.07
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | 48 weeks | | 0.80 ± 0.04 | | 0.75 ± 0.06
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | 13) Proteinuria: Urine albumin/creatinine ratio
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | | | Perindopril | | Telmisartan
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | Baseline | | 23.8 ± 8.3 | | 58.2 ± 34.1
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | 24 weeks | | 40.8 ± 23.2 | | 55.5 ± 34.2
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | 48 weeks | | 41.5 ± 21.8 | | 47.9 ± 28.5
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months
Nakamura, Kawachi, Saito, et al., 2009 #19 | | Recruitment setting: NR Inclusion criteria:; - Essential HTN (SBP > 140 or DBP > 90); Exclusion criteria:; - Secondary HTN; - ACEI or ARB in past 6 months | | | | | Between-groups comparison not statistically significant

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Neutel, Frishman, Oparil, et al., 1999 #1605 | Geographical location: 44 centers across US Study dates: NR Funding source: NR Interventions:; - Telmisartan 40-160 mg qd (n = 385); - Lisinopril 10-40 mg qd (n = 193); Dosage titration and co-interventions: At wk 4, patients with uncontrolled DBP (≥ 90 mm Hg) were titrated to dose level 2 (telmisartan 80 mg, lisinopril 20 mg); if DBP still uncontrolled at wk 8, then titrated to dose level 3 (telmisartan 160 mg, lisinopril 40 mg). If DBP still uncontrolled at wk 12, but DBP reduced by ≥ 10 mm Hg from baseline, then HCTZ 12.5 mg added; remaining uncontrolled patients dropped from study. For patients on HCTZ, this could be titrated up to 25 mg if BP control lost during maintenance phase. If DBP ≥ 90 mm Hg on 2 consecutive study visit while patient taking max dose of HCTZ, then patient dropped from study Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: No; Was allocation concealment adequate?: NR Baseline/run-in period: 2- to 14-day withdrawal of previous antihypertensive med; 4-wk placebo run-in Duration of treatment: 48 wk after dose titration achieved Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 578; - Began treatment: 578; - Completed treatment: 448?; - Withdrawals/losses to followup: 136 during dose-titration period (125 treatment failures, 11 no post-randomization BP data); 25 during maintenance phase (protocol deviations or invalid data); Age: Mean (SD): 53.5 Median: NR Range: NR Sex (n [%]): Female: 195 (34%) Male: 383 (66%) Race/ethnicity (n [%]): White: 433 (75%) Black: 102 (18%) Hispanic: 35 (6% Other: 8 (1%) Baseline blood pressure: Supine BP measured 3 times at 2-min intervals after patient rested in supine position for 5 min using mercury sphygmomanometer; average of 3 readings used | | | | | 1) Blood pressure: Mean change in BP at 48 wk (in mm Hg; all analyzable completers, n's uncertain): | | | | | | General comments:; - Study excluded large number of patients post-randomization who failed to respond to treatment (DBP ≥ 90); Quality assessment: Overall rating: Fair Comments:; - Randomization not described; - Large number of non-responders excluded post-randomization; - N's unclear for many outcomes; Applicability:; - Recruitment not described; - Non-responders excluded during study; - Supine BP used
Neutel, Frishman, Oparil, et al., 1999 #1605 | | | | | | | | | Telmisartan | | Lisinopril
Neutel, Frishman, Oparil, et al., 1999 #1605 | | | | | | | SBP | | -21.1 | | -19.3
Neutel, Frishman, Oparil, et al., 1999 #1605 | | | | | | | DBP | | -16.3 | | -15.4
Neutel, Frishman, Oparil, et al., 1999 #1605 | | | | | | | p = NS
Neutel, Frishman, Oparil, et al., 1999 #1605 | | | | | | | Mean change in BP at 48 wk among patients who completed on monotherapy (in mm Hg; n's uncertain):
Neutel, Frishman, Oparil, et al., 1999 #1605 | | | | | | | | | Telmisartan | | Lisinopril
Neutel, Frishman, Oparil, et al., 1999 #1605 | | | | | | | SBP | | -17.7 | | -18.6
Neutel, Frishman, Oparil, et al., 1999 #1605 | | | | | | | DBP | | -15.9 | | -15.5
Neutel, Frishman, Oparil, et al., 1999 #1605 | | | | | | | 2) Rate of use of a single antihypertensive agent for BP control: Telmisartan: 44% Lisinopril: 48% 3) Mortality: NR 4) Morbidity: NR 5) Safety: Drug-related AEs: Telmisartan: 28% Lisinopril: 40% p = 0.001 Discontinuations due to cough: Telmisartan: 0.3% Lisinopril: 3.1% p = 0.007 Discontinuations due to angioedema: Telmisartan: 0 Lisinopril: 2 patients 6) Specific adverse events: AEs considered to be drug-related:
Neutel, Frishman, Oparil, et al., 1999 #1605 | | | [underlined: Telmisartan] | | [underlined: Lisinopril]
Neutel, Frishman, Oparil, et al., 1999 #1605 | | SBP | 153.4 | | 152.5
Neutel, Frishman, Oparil, et al., 1999 #1605 | | DBP | 100.8 | | 100.5
Neutel, Frishman, Oparil, et al., 1999 #1605 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR- 44 centers Inclusion criteria:; - Mean supine DBP 95-114 on placebo (run-in period); Exclusion criteria:; - Secondary hypertension; - Patients excluded at various points during study if DBP ≥ 90
Neutel, Frishman, Oparil, et al., 1999 #1605 | | | | | | | | | Telmisartan [underlined: (n = 385), %] | | Lisinopril [underlined: (n = 193), %]
Neutel, Frishman, Oparil, et al., 1999 #1605 | | | | | | | Impotence | | 3 | | 2
Neutel, Frishman, Oparil, et al., 1999 #1605 | | | | | | | Headache | | 5 | | 6
Neutel, Frishman, Oparil, et al., 1999 #1605 | | | | | | | Fatigue | | 4 | | 7
Neutel, Frishman, Oparil, et al., 1999 #1605 | | | | | | | Cough | | 3 | | 7^*^
Neutel, Frishman, Oparil, et al., 1999 #1605 | | | | | | | Dizzy | | 7 | | 8
Neutel, Frishman, Oparil, et al., 1999 #1605 | | | | | | | Dyspepsia | | 0 | | 2
Neutel, Frishman, Oparil, et al., 1999 #1605 | | | | | | | ^*^p = 0.18 vs. telmisartan 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Onal, Altun, Onal, et al., 2009 #27 | Geographical location: Ankara, Turkey Study dates: NR Funding source: LUT 04/61, Turkish Hypertension and Kidney Disease Foundation, Astra Zeneca Interventions:; - Candesartan 8-16 mg/day (n = 17); - Lisinopril 10-20 mg/day (n = 16); - Age- and sex-matched controls (normotensive n = 16); Were additional anti-hypertension medications allowed: No Study design: RCT, parallel-group Blinding:; - Patients: NR; - Providers: NR; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: 1 week washout at start of trial if on any BP medication Duration of treatment: 3 months Duration of post-treatment followup: NA | Number of patients: N = 49; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 33; - Began treatment: 33; - Completed treatment: 33; - Withdrawals/losses to followup: 0; Age: Mean (SD): Hypertensive: 47 ±8 Normotensive: 42 ±10 Sex (n [%]): Hypertensive: Female: 22 (66.6%) Male: 11 (33.3%) All: Female: 31 (63.3%) Male: 18 (36.7%) Race/ethnicity (n [%]): NR Baseline blood pressure: Mean (SD) | | | | | 1) Blood pressure: Mean (SD) | | | | | | General comments:; - Recruitment, randomization, and blinding were not described; - Baseline demographics not described for 2 intervention arms; - Small study and short duration; - BP measures not described well; - Randomized; all patients had complete data; Quality assessment: Overall rating: Fair Comments: See general comments Applicability:; - Recruitment/screening not described; - Unable to assess baseline confounders between groups; - Small study with no differences between groups noted (Type 2 error possible)
Onal, Altun, Onal, et al., 2009 #27
Onal, Altun, Onal, et al., 2009 #27 | | | | | | | | | SBP | | DBP
Onal, Altun, Onal, et al., 2009 #27
Onal, Altun, Onal, et al., 2009 #27 | | | | | | | Candesartan | | 117 (6) | | 72 (5)
Onal, Altun, Onal, et al., 2009 #27
Onal, Altun, Onal, et al., 2009 #27 | | | | | | | Lisinopril | | 120 (9) | | 77 (6)
Onal, Altun, Onal, et al., 2009 #27
Onal, Altun, Onal, et al., 2009 #27 | | | | | | | There were no statistically significant differences between the medications. 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Onal, Altun, Onal, et al., 2009 #27
Onal, Altun, Onal, et al., 2009 #27 | | | SBP | | DBP
Onal, Altun, Onal, et al., 2009 #27
Onal, Altun, Onal, et al., 2009 #27 | | Candesartan | 127 (6) | | 81 (6)
Onal, Altun, Onal, et al., 2009 #27
Onal, Altun, Onal, et al., 2009 #27 | | Lisinopril | 131 (11) | | 84 (7)
Onal, Altun, Onal, et al., 2009 #27
Onal, Altun, Onal, et al., 2009 #27 | | Concurrent non-hypertension medications (n [%]): None Comorbidities (n [%]): NR Recruitment setting: Nephrology and general medicine outpatient clinics at Hacettepe University Hospital Inclusion criteria: Stage 1 HTN diagnosed after 24 h ambulatory blood pressure monitoring (ABPM), and was defined as having systolic and diastolic BPs over 140/90 mm Hg during the day or 120/80 mm Hg at night. For patients on BP medication, measurement occurred after stopping treatment for 1 week. Exclusion criteria:; - Renal insufficiency of stage 2 and above; - Hypertension of stage 2 and above - Diabetes; - Signs or symptoms of cardiovascular, neoplastic or connective tissue disease, and of any evidence of organ fibrosis; - Required use of antihypertensive drugs other than ACEI or ARB

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Ozturk, Sar, Bengi-Bozkurt, et al., 2009 #1667 | Geographical location: NR (authors from Turkey) Study dates: NR Funding source: NR Interventions:; 1. ACEI prescribed (N = 59); 2. ARB prescribed (N = 41); Were additional anti-hypertension medications allowed: Yes If Yes to above, was this done: At discretion of clinician/investigator “19 of the ACEI group (32%) and 15 of the ARB group (36%) were taking non-dihydopyridine class calcium channel blockers, and 29 of the ACEI group (49%) and 22 of the ARB group (53%) were taking other antihypertensive drugs” Study design: Retrospective chart review Blinding:; - Patients: NA; - Providers: NA; - Assessors of outcomes: No; Was allocation concealment adequate?: NA Baseline/run-in period: NA Washout period(s): NA Duration of treatment: Mean duration of followup 24.6 months (SD = 14.1) Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: 289 charts reviewed retrospectively; - Eligible for inclusion: 100; - Randomized: NA; - Began treatment: 100; - Completed treatment: 100; - Withdrawals/losses to followup: 15 (11/59 = 19% in the ACEI group, and 4/41 = 10% in the ARB group); Age: Mean (SD): 61.8 (9.16) Median: NR Range: NR Sex (n [%]): Female: 45 (45%) Male: 55 (55%) Race/ethnicity (n [%]): NR Baseline blood pressure: SBP, mean (SD): ACEI: 150 (27) ARB: 152 (22) P = 0.650 DBP, mean (SD): ACEI: 85 (10) ARB: 87 (13) P = 0.388 Concurrent non-hypertension medications (n [%]): 42 patients of the ACEI group (71%) and 35 of the ARB group (85%) were taking statins Comorbidities (n [%]): See inclusion criteria below. Mean duration of awareness of DM = 15.7 years. Recruitment setting: Outpatient nephrology clinic Inclusion criteria:; - Diabetic nephropathy, defined as type II diabetes, creatinine clearance <90 ml/min, and diabetic retinopathy; - SBP ≥ 140 and/or DBP ≥ 90 mm Hg, or had been using anti-HTN drug(s) for HTN; - Followed for at least 16 months and evaluated at least twice in the outpatient clinic prior to study entry; Exclusion criteria:; - Followed for < 6 months prior to study entry; - Using an ACEI and ARB concurrently; - Could not use an ACE or ARB for > 4 weeks; - SBP < 140 mm and DBP < 90 at presentation; - Any renal disease other than diabetic nephropathy (DNP) or any disease that might affect renal function independent of DNP; - Non-diabetes-related renal or systemic comorbidities; - Prior use of aldosterone blockers.; - History of switching from ACEI to ARB or vice-versa; Prior use of an ACE or ARB was not an exclusion criterion | | | | | 1) Blood pressure: “The course of mean SBP and DBP throughout the study was similar (147.9 ± 16.5/83.3 ± 12.9 mm Hg in the ACEI group and 147.5 ± 16.0/83.7 ± 7.5 mm Hg in the ARB group; p = NS). At the last check, mean BP…was 135.8 ± 14.6/80.8 ± 10.1 mm Hg in the ACEI group, 140.0 ± 22.5/80.0 ± 5.3 mm Hg in the ARB group).” 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: ACEI: 2/59 (3.4%) ARB: 2/41 (4.9%) 4) Morbidity: Incidence of dialysis during study period: ACEI: 7/59 (12%) ARB: 3/41 (7%) P = 0.20 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: Reasons for losses to followup or withdrawal not reported. 8) Lipid levels: NR 9) Progression to type 2 diabetes: NA (all patients had DM) 10) Markers of carbohydrate metabolism/diabetes control: Baseline HbA1c, g/dL (SD): ACEI: 8.31 (1.84) ARB: 7.58 (1.62) P = 0.118 Followup HbA1c, g/dL (SD): ACEI: 7.9 (1.4) ARB: 7.73 (1.2) P = NS 11) LV mass/function: NR 12) Creatinine/GFR: Baseline creatinine, mg/dl (SD): ACEI: 1.75 (0.65) ARB: 1.66 (0.49) P = 0.441 Followup creatinine, mg/dl (SD): ACEI: 1.89 (0.86) ARB: 1.77 (0.62) P = NS Baseline estimated creatinine clearance, ml/min (SD): ACEI: 48.7 (17.5) ARB: 53.2 (16.7) P = 0.203 Followup estimated creatinine clearance, ml/min (SD): ACEI: 48.1 (18.1) ARB: 52.8 (17.6) P = NS 13) Proteinuria: Baseline proteinuria, mg/day (SD): ACEI: 657 (1,871) ARB: 712 (3,184) P = 0.563 Followup proteinuria, mg/day (SD): ACEI: 307 (2,362) ARB: 466 (2,126) P = NS “Although proteinuria decreased by 77% in the ACEI group and by 27% in the ARB group at 48 months (only 5 patients in the ACEI group and 6 patients in the ARB group could be followed until the 48^th^ month, after the exclusion of those on dialysis or dead patients) in the statistical analysis, mean daily proteinuria did not show significant differences between both groups throughout the study.” | | | | | | General comments: None Quality assessment: Overall rating: Poor Comments:; - Retrospective chart review (although it is possible that patients were followed prospectively—the reporting is ambiguous); - Inadequate reporting of methods and results; - Possibility of significant selection bias; Applicability:; - Study conducted in Turkey (by inference); - Individual drugs not reported; results reported only as ACEI vs. ARB drugs

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Patel, Remigio-Baker, Mehta, et al., 2007 #173 | Geographical location: Records examined from across US Study dates: Jan 1, 2001 – Dec 31, 2003 Funding source: Novartis Pharmaceuticals Corporation Interventions: ARB: 10,245 (4.2%) ACEI: 78,616 (32.4%) CCB: 36,246 (14.9%) BB: 82,841 (34.1%) Diuretic: 34,934 (14.4%) Were additional anti-hypertension medications allowed: Yes If Yes to above, was this done: At discretion of clinician Study design: Other – retrospective longitudinal cohort study Blinding: NA Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: 1 year Duration of post-treatment followup: NA | Number of patients: N = 242,882; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: NR; - Began treatment: NR; - Completed treatment: NR; - Withdrawals/losses to followup: NR; Age: Mean (SD): 54.9 ±15.7 Sex (n [%]): Female: 138,071 (56.8%) Male: 104,811 (43.2%) Race/ethnicity (n [%]): NR Baseline blood pressure: NR Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): 78% of the study population had at least 1 comorbid condition with hypertension Recruitment setting:; - Data drawn from the administrative pharmacy claims database from MedImpact, a large national pharmacy benefits manager that administers prescription benefit coverage to approximately 27 million persons across the United States; - Database comprised employer corporations; unions; managed care organizations; health plans; insurance carriers; third-party administrators; and local, state, and federal employee programs; Inclusion criteria:; - Patients previously naïve to antihypertensive therapy; - Started therapy with an ACEI, ARB, calcium channel blocker (CCB), b-blocker (BB), or diuretic; - Age > 18 years; - Filled at least 1 prescription for a target medication during the 3-year study identification period of Jan 1, 2001, through Dec 31, 2003; - Continuously benefit-eligible for at least 6 months preceding and 12 months following the index date; Exclusion criteria: Claims for any target antihypertensive medications during the 6 months before their index date | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: 51.9% of ARB patients were persistent with their index therapy at 12 months, compared with 48.0% of ACEI patients, 40.3% of BB patients, 38.3% of CCB patients, and 29.9% of diuretic patients (no p value for comparison) After adjustment for covariates and compared with diuretic users, patients receiving an ARB were 52% more likely to be persistent, patients receiving an ACEI were 43% more likely to be persistent (no p value for comparison) The mean medication possession ratio (MPR) was similar for ACEI (59.2) and ARB (58.9) patients (no p value for comparison) Adjusted for covariates, the MPRs for patients receiving ARBs and ACEIs were not significantly different (no p value for comparison) but were higher than other drug classes (p < 0.0001) The percentage of patients classified as adherent (MPR > 80%) was similar for patients receiving ACEIs (39.2%) and ARBs (38.5%) (no p value for comparison) ARB patients had the longest time to therapy discontinuation (mean = 236.9 days), compared with patients utilizing other drug classes (no p value for comparison) Compared with patients who started diuretic therapy, patients who began antihypertensive monotherapy with ARBs (HR, 0.59; P < 0.0001), ACEIs (HR, 0.64; P < 0.0001), CCBs (HR, 0.86; P < 0.0001), or BBs (HR, 0.82; P < 0.0001) were all significantly less likely to discontinue their index therapy Most patients who discontinued index therapy did so within the first 30 days of starting therapy 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | | General comments:; - Good design and dataset for research question; - Adequate followup; - Patient sample well defined and fairly similar among groups; - Objective outcome criteria; - Propensity scores used to match patients among BP drug class cohorts; - Appropriate statistical analysis EXCEPT…; - unable to confirm diagnosis of HTN (no clinic data); - Mostly descriptive data were reported without statistical testing. Results section uses terms “more” and “similar” but statistical testing was reported only twice, and it was for comparison of ACEI and ARB vs. others or each BP drug class vs. diuretics; Quality assessment: Overall rating: Fair (Good if statistical testing was reported to back up comparison comments) Comments: None Applicability:; - Unable to verify comparison comments made in text because statistical testing not reported; - Because study uses administrative data, unable to determine for certain whether discontinuation of therapy was due to AEs or other factors

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Rabbia, Silke, Carra, et al., 2004 #1607 | Geographical location: NR; investigators from Italy and Ireland Study dates: NR Funding source: No external funding Interventions:; - Fosinopril 10-20 mg (n = 19); - Irbesartan 150-300 mg (n = 19); - Atenolol 50-100 mg (n = 20) All once daily at 8 am; Doses doubled if office BP was ≥ 140/90 mm No sodium or liquid intake restriction Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: No; Was allocation concealment adequate?: NR Baseline/run-in period: 2-wk placebo-run-in period Duration of treatment: 14 weeks Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 58; - Began treatment: NR; - Completed treatment: NR; - Withdrawals/losses to followup: NR; Age: Mean (SD): 38 ± 10 yr Median: NR Range: NR Sex (n [%]): Female: 27 Male: 31 Race/ethnicity (n [%]): NR Baseline blood pressure: Office BP measured 3 times by same physician in sitting position after 10 min of rest using a mercury sphygmomanometer, disappearance of phase V Korotkoff sound = diastolic pressure Baseline values: | | | | | 1) Blood pressure: Office BP at 14 wk (p < 0.001 for all comparisons with baseline): | | | | | | General comments:; - No racial distribution; - Setting of study; no description (country? system? center selection? study clinicians?); - No data regarding numbers of patients screened, eligible for inclusion, or lost to followup; Quality assessment: Overall rating: Fair Comments:; - Setting of trial not described; - Single-blind; Applicability:; - Race of patients not mentioned
Rabbia, Silke, Carra, et al., 2004 #1607 | | | | | | | | | [underlined: Fosinopril] | | [underlined: Irbesartan]
Rabbia, Silke, Carra, et al., 2004 #1607 | | | | | | | SBP: | | 129 ± 7 | | 133 ± 9
Rabbia, Silke, Carra, et al., 2004 #1607 | | | | | | | DBP: | | 85 ± 4 | | 87 ± 8
Rabbia, Silke, Carra, et al., 2004 #1607 | | | | | | | 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: Nr 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Rabbia, Silke, Carra, et al., 2004 #1607 | | | [underlined: Fosinopril] | | [underlined: Irbesartan]
Rabbia, Silke, Carra, et al., 2004 #1607 | | SBP: | 152 ± 11 | | 151 ± 11
Rabbia, Silke, Carra, et al., 2004 #1607 | | DBP: | 97 ± 7 | | 97 ± 6
Rabbia, Silke, Carra, et al., 2004 #1607 | | ABPM obtained for 24 hr (results also reported) Concurrent medications (n [%]): None allowed during study Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria:; - Never treated mild hypertension with no evidence of target organ damage; - SBP and DBP were ≥ 140 and ≥ 90 mm, respectively, on 3 consecutive days (3 measurements /day separated by 10-mm interval) after 15 min sitting position; Exclusion criteria:; - Clinical, biochemical, ECG or radiological evidence of end-organ damage or reported history of coronary artery disease; - History of heavy alcohol consumption; - Sec. hypertension def. as ABPM < 130/80 with persistently elevated office BP) and poor sleep quality during ABPM; - No medications allowed during study

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Ragot, Ezzaher, Meunier, et al., 2002 #1608 | Geographical location: 105 outpatient French Centers Study dates: NR Funding source: NR Interventions:; - Telmisartan 40-80 mg (n =220); - Perindopril 4-8 mg (n = 221); Doses doubled at 6 wk if necessary Study design: RCT, parallel-group Blinding:; - Patients: NR; - Providers: NR; - Assessors of outcomes: No – patients self measure BP; Was allocation concealment adequate?: Yes - IVRS Baseline/run-in period: 3-wk run-in placebo period sitting DBP ≥ 90 and ≤ 110 and SBP < 180 Duration of treatment: 12 wk Duration of post-treatment followup: NR | Number of patients:; - Screened for inclusion: 671; - Eligible for inclusion: 441; - Randomized: 441; - Began treatment: 441; - Completed treatment: NR; - Withdrawals/losses to followup: 73, 5 no BP measurements on treatment, 1 did not receive study med, 54 due to poor quality self BP measurement, 13 due to unspecified protocol violations; - Per protocol population = 368; Age: Mean (SD): 55.3 ± 11.8 Median: NR Range: NR Sex (n [%]): Female: 197/435 (45%) Male: 238/435 (ITT pop) (55%) Race/ethnicity (n [%]): 421/435 = 97.5% white Baseline blood pressure: Trough office BP assessed using semiautomatic device (OMRON 705 CP); 3 measurements taken at 1-min intervals with patient sitting and after 5 min rest; mean analyzed | | | | | 1) Blood pressure: Mean trough office BP at 12 wk (taken from Fig 3; SDs not reported): | | | | | | General comments:; - Focus of article was comparison of self-measurement of BP and office measurement; Quality assessment: Overall rating: Poor Comments:; - Not blinded; - Large number of patients (n = 59) excluded from per-protocol analysis due to poor quality self-measurement of BP; Applicability:; - Results are more applicable than most of HTN trials review in that co-morbidities are presented in baseline table
Ragot, Ezzaher, Meunier, et al., 2002 #1608 | | | | | | | | | Telmisartan [underlined: (n = 217)] | | Perindopril [underlined: (n = 218)] | [underlined: P-value]
Ragot, Ezzaher, Meunier, et al., 2002 #1608 | | | | | | | SBP | | 144.0 | | 148.0 | p < 0.05
Ragot, Ezzaher, Meunier, et al., 2002 #1608 | | | | | | | DBP | | 88.7 | | 91.3 | p < 0.005
Ragot, Ezzaher, Meunier, et al., 2002 #1608 | | | | | | | Mean decrease in trough office DBP from baseline to 12 wk: Telmisartan: - 8.8 mm Hg Perindopril: -6.3 mm Hg p = 0.002 Adjusted mean difference (telmisartan vs. perindopril) for reduction in trough office SBP was -3.4 mm Hg (p = 0.016). Mean decreases NR. Normalized SBP at 12 wk (SBP < 140 mm Hg): Telmisartan: 97/217 (45%) Perindopril: 67/218 (31%) p < 0.005 Normalized DBP at 12 wk (DBP < 90 mm Hg): Telmisartan: 122/217 (56%) Perindopril: 96/218 (44%) p < 0.01 Results for self-BP measurement also reported 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: Any AE: Telmisartan: 74 (34%) Perindopril: 70 (32%) 6) Specific adverse events: Cough: Telmisartan: 2 (< 1%) Perindopril: 12 (5%) p = 0.007 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Ragot, Ezzaher, Meunier, et al., 2002 #1608 | | | Telmisartan (n = 217) | | Perindopril (n = 218)
Ragot, Ezzaher, Meunier, et al., 2002 #1608
Ragot, Ezzaher, Meunier, et al., 2002 #1608 | | SBP | 158 ± 13 | | 159 ± 13
Ragot, Ezzaher, Meunier, et al., 2002 #1608 | | DBP | 98 ± 6 | | 98 ± 6
Ragot, Ezzaher, Meunier, et al., 2002 #1608 | | Concurrent medications (n [%]): Anti-HTN therapy prior to study entry: 236 (54%) Comorbidities (n [%]): Obesity 111 (25.5%) History of CV events 58 (13.5%) Type II DM 27 (6.5%) Recruitment setting: Outpatient French clinics Inclusion criteria:; - Age ≥ 18 yr; - Mild-moderate hypertension; - Inadequate BP control or treatment side effect; - 3-wk run-in placebo period sitting DBP ≥ 90 and ≤ 110 and SBP < 180; Exclusion criteria:; - Patients with self BP measurement of poor quality during run-in period, poor compliance with treatment during run-in period; - History of non response to ACEI or ARB; - Suspicion of secondary HTN; - Biliary disease; - Non-postmenopausal women not using reliable contraception

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #1609 | Geographical location: Krakow, Poland Study dates: NR Funding source: University grant Interventions:; - Quinapril 20 mg qd (n = 38 BP responders); - Losartan 100 mg (50 mg bid) (n = 24 BP responders); - Amlodipine 10 mg qd (n = 37 BP responders); Dose titration and co-interventions: None, as subjects represent subgroup from larger trial who responded (BP ≤ 140/90 mm Hg) to monotherapy at 3 mo Study design: RCT, parallel-group Blinding:; - Patients: No; - Providers: Yes; - Assessors of outcomes: Yes; Was allocation concealment adequate?: NR Baseline/run-in period: 2-wk antihypertensive-free run-in period Duration of treatment: 6 mo Duration of post-treatment followup: NR | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 118 (for the larger study); - Began treatment: NR; - Completed treatment: NR; - Withdrawals/losses to followup: NR; Age (n = 118 larger trial): Mean (SD): 53.7 ± 9.06 Median: NR Range: NR Sex (n [%]; n = 118 larger trial)^*^: Female: 64 (54%) Male: 54 (46%) Race/ethnicity (n [%]): NR, but presumably 100% white Baseline blood pressure: Mean of 3 sphygmomanometer measurements “in standard conditions” Mean baseline values: | | | | | 1) Blood pressure: Mean BP at 3 mo: | | | | | | General comments:; - Subgroup analysis of patients from a larger trial who responded to monotherapy at 3 mo (99/118); - Focus of article is effect of treatment on pulse wave velocity and plasma collagen markers; Quality assessment: Overall rating: Poor Comments:; - No information on recruitment setting, exclusion criteria, or comorbidities; - No data on safety/AEs; - Inclusion of only responders to monotherapy biases the results toward the null hypothesis of no difference in BP response, especially since there were fewer responders in the losartan group; Applicability:; - Subgroup of patients who responded to monotherapy; - No information on recruitment setting, exclusion criteria, or comorbidities
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #1609 | | | | | | | | | Quinapril [underlined: (n = 38)] | | Losartan [underlined: (n = 24)]
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #1609 | | | | | | | SBP | | 141 ± 23.7 | | 132 ± 15.8
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #1609 | | | | | | | DBP | | 92 ± 8.7 | | 83 ± 9.2
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #1609 | | | | | | | Mean BP at 6 mo:
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #1609 | | | | | | | | | Quinapril [underlined: (n = 38)] | | Losartan [underlined: (n = 24)]
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #1609 | | | | | | | SBP | | 113 ± 14.6 | | 125 ± 16.8
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #1609 | | | | | | | DBP | | 86 ± 7.1 | | 84 ± 8.1
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #1609 | | | | | | | No significant differences between groups for decrease from baseline at either timepoint (p-values NR) 24-hr ABPM values also reported 2) Rate of use of a single antihypertensive agent for BP control: NA (response to monotherapy was the criterion for inclusion in this subgroup report) 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: Measured but NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: LVMI was comparable across groups at baseline (116.9 ± 23.9 g/m^2^) and did not change at 6 mo for any of the groups (data not shown) 12) Creatinine/GFR: NR 13) Proteinuria: NR
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #1609 | | | Quinapril [underlined: (n = 38)] | | Losartan [underlined: (n = 24)]
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #1609 | | SBP | 154 ± 22.5 | | 155 ± 18.6
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #1609 | | DBP | 97 ± 14.1 | | 91 ± 13.5
Rajzer, Klocek, and Kawecka-Jaszcz, 2003 #1609 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria:; - Mild to moderate hypertension according to WHO/ISH guidelines; - BP adequately controlled (BP ≤ 140/90 mm Hg at 3 mo) on study drug monotherapy; Exclusion criteria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Rehman, Ismail, Naing, et al., 2007 #221 | Geographical location: Kelantan, Malaysia Study dates: NR Funding source: Intensification of Research in Priority Areas (IRPA), Ministry of Health, Malaysia Interventions:; - Losartan 50 mg daily (n = 19); - Perindopril 4 mg daily (n = 20); Blood pressure was assessed every month and dose of antihypertensive was increased to achieve a target blood pressure of 140/90 mm Hg Were additional anti-hypertension medications allowed: Yes If Yes to above, was this done: Per protocol: “If required a diuretic (indapamide 1.5) followed by a third antihypertensive was added in a stepwise manner on the subsequent visits.” Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: 2-week washout at start of trial Duration of treatment: 4 months Duration of post-treatment followup: NA | Number of patients: N = 39; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 46; - Began treatment: 46; - Completed treatment: 39; - Withdrawals/losses to followup: 7; Age: Mean (SD): 52.78 (7.96) Sex (n [%]): Female: NR Male: NR Race/ethnicity (n [%]): NR Baseline blood pressure: | | | | | 1) Blood pressure: Month 0 – Month 4 changes: | | | | | | General comments:; - May not have used true randomization based on statement, “The ratio of subjects studied in each arm was kept equal”; - Small study did not detect differences between groups so may suffer from Type 2 error; - Moderate dropout (15%); - Completer analysis only; - ITT analysis not stated; - Double-blinded; - Groups equal at baseline and treated equally; Quality assessment: Overall rating: Fair Comments: See General comments, above Applicability:; - Recruitment not described; - Took place in Malaysia; - Excluded patients with A1166C polymorphism (not reported how common this is)
Rehman, Ismail, Naing, et al., 2007 #221 | | | | | | | | | [underlined: Losartan] | [underlined: p value] | [underlined: Perindopril] | [underlined: p value]
Rehman, Ismail, Naing, et al., 2007 #221 | | | | | | | SBP | | 14 (15.97) | 0.002 | 18 (12.26) | < 0.001
Rehman, Ismail, Naing, et al., 2007 #221 | | | | | | | DBP | | 8 (8.54) | 0.001 | 9 (6.23) | < 0.001
Rehman, Ismail, Naing, et al., 2007 #221 | | | | | | | PP | | 5 (12.34) | 0.077 | 9 (11.15) | 0.002
Rehman, Ismail, Naing, et al., 2007 #221 | | | | | | | PWV | | 0.83 (1.19) | 0.007 | 0.57 (1.22) | 0.047
Rehman, Ismail, Naing, et al., 2007 #221 | | | | | | | PWVa | | 0.82 (1.18) | 0.042 | 0.57 (1.22) | 0.043
Rehman, Ismail, Naing, et al., 2007 #221 | | | | | | | Comparisons between groups were NS 72% achieved target blood pressure of 140/90 mm Hg The remaining 28% of the subjects were equally distributed in the two treatment arms 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Rehman, Ismail, Naing, et al., 2007 #221 | | | [underlined: Losartan] | | [underlined: Perindopril]
Rehman, Ismail, Naing, et al., 2007 #221 | | SBP | 151 (13.91) | | 152 (12.21)
Rehman, Ismail, Naing, et al., 2007 #221 | | DBP | 94 (10.37) | | 92 (7.54)
Rehman, Ismail, Naing, et al., 2007 #221 | | The patients were allowed to rest for 10 to 15 min in supine position to achieve basal body conditions. Systolic and diastolic blood pressure were measured using mercury column sphygmomanometer (Baumanometer, W.A. Baum Co. Inc., Copiague, New York) according to JNC VI guidelines. Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria:; - Mild to moderate hypertension without evidence of cardiovascular complications; - All subjects were homozygous for AT1R A1166C polymorphism (wild type); Exclusion criteria:; - Hypertensive target organ damage, acute infection, respiratory or endocrine illness, renal, or hepatic dysfunction; - Presence of A1166C polymorphism; - Previously treated with either an ACEI or an ARB; - On treatment with lipid-lowering drugs, psychotropic agents, antidepressants, nonsteroidal inflammatory drugs, steroids, or hormones; - Severe or secondary hypertension, severe hyperlipidemia (total cholesterol >7.5 mmol/L) or other factors that made measurement of PWV technically difficult such as body mass index (BMI) > 35 kg/m^2^, atrial fibrillation, peripheral vascular disease, and hematocrit < 30 or > 50 g/dL

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Robles, Angulo, Grois, et al., 2004 #1610 | Geographical location: Badajoz, Spain Study dates: NR Funding source: NR Interventions:; - Irbesartan 150 mg/day (n = 15); - Fosinopril 20 mg/day (n = 15); After 4 weeks: If BP ≥ 140/90 titrated by adding 12.5mg/day After 8 weeks: Non-controlled patients excluded Sodium intake limited Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: NR; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: After withdrawal of any antihypertensive therapy, if needed, eligible patients entered a 2-week washout phase Duration of treatment: 12 weeks Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 30; - Began treatment: NR; - Completed treatment: NR; - Withdrawals/losses to followup: NR; Age: Mean: 61.3 yr Median: NR Range: NR Sex (n [%]): Female: 15 Male: 15 Race/ethnicity (n [%]): NR Baseline blood pressure: Method of assessment NR | | | | | 1) Blood pressure: BP at 12 wk (method of assessment NR; p < 0.001 for all comparisons vs. baseline): | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments:; - Setting and some of the subjects not described; Applicability:; - Primary objective: effect of drugs on hematopoiesis; - Setting and some of the subjects not described
Robles, Angulo, Grois, et al., 2004 #1610 | | | | | | | | | [underlined: Irbesartan] | | [underlined: Fosinopril]
Robles, Angulo, Grois, et al., 2004 #1610 | | | | | | | SBP: | | 131.0 ± 8.7 | | 132.2 ± 12.4
Robles, Angulo, Grois, et al., 2004 #1610 | | | | | | | DBP: | | 82.7 ± 4.2 | | 84.0 ± 5.4
Robles, Angulo, Grois, et al., 2004 #1610 | | | | | | | 2) Rate of use of a single antihypertensive agent for BP control: HCTZ was added to 6 pts with inadequate BP control at 4 wk (3 in Irb gp) and 8^th^ wk (2 in Irb gp and 1 in Fos gp) 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Robles, Angulo, Grois, et al., 2004 #1610 | | | [underlined: Irbesartan] | | [underlined: Fosinopril]
Robles, Angulo, Grois, et al., 2004 #1610 | | SBP: | 157.7 ± 11.2 | | 147.9 ± 11.7
Robles, Angulo, Grois, et al., 2004 #1610 | | DBP: | 94.1 ± 5.6 | | 92.3 ± 6.3
Robles, Angulo, Grois, et al., 2004 #1610 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria:; - Mild or moderate essential HTN (BP ≥ 140/90 and < 180/100); Exclusion criteria:; - Creatinine ≥ 1.5 mg/dL; - Unstable angina; - MI/stroke in last 3 mo; - Heart failure; - Hypokalemia; - COPD; - Hematological disease; - Hb ≤ 13 gm or >17 gm; - Hypersensitivity to test drugs; - Pre-menopausal women

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Roca-Cusachs, Oigman, Lepe, et al., 1997 #1611 | Geographical location: Multicenter, with sites in Spain, Austria, Brazil, Czech Republic, China, Colombia, Croatia, Dominican Republic, Ecuador, Jamaica, Mexico, Pakistan, Peru, Russia, Slovak Republic, Slovenia, Taiwan, Ukraine, UAE Study dates: NR Funding source: Merck & Co Interventions:; - Losartan 50-100 mg (n = 192); - Captopril 25 mg twice daily-50 mg twice daily (n = 204); Dose titration and co-interventions: Titrated to higher dose at 6 wk if seated DBP ≥ 90; no other antihypertensives allowed Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: 1-wk drug washout; 4-wk placebo run-in Duration of treatment: 12 wk Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 396; - Began treatment: 396; - Completed treatment: 356; - Withdrawals/losses to followup: 40 (17 due to AEs, 7 lost to followup, 7 insufficient response, 7 protocol violations, 2 uncooperative); Age: Mean (SD): 51.4 (10.9) Median: NR Range: NR Sex (n [%]): Female: 174 (44%) Male: 222 (56%) Race/ethnicity (n [%]): Black: 36 (9%) Non-black: 360 (91%) Baseline blood pressure: Trough seated BP assessed using mercury sphygmomanometer after 5-min rest; average of 3 readings | | | | | 1) Blood pressure: Main results in Figure 1 (change in seated DBP) and Figure 2 (change in seated SBP), but mean posttreatment BP values NR in tables or text. Mean change in seated BP from baseline to 12 wk: | | | | | | General comments:; - Patients withdrawn if DBP not ≥ 95 during placebo run-in period resulting in some potential exclusions; - Primary outcome was change in DBP/SBP, but one wonders if this was established a priori since final SBP/DBP are not reported in study.; Quality assessment: Overall rating: Fair Comments:; - Numbers screened and eligible NR; Applicability:; - Minimal racial diversity (91% Caucasian); - Recuitment setting(s) not described; - Minimal comorbities in study population; difficult to extrapolate to the general population
Roca-Cusachs, Oigman, Lepe, et al., 1997 #1611 | | | | | | | | | | Losartan (n = 190) | Captopril (n = 203) | P-value
Roca-Cusachs, Oigman, Lepe, et al., 1997 #1611
Roca-Cusachs, Oigman, Lepe, et al., 1997 #1611 | | | | | | | SBP | | | -15.4 | -12.2 | = 0.023
Roca-Cusachs, Oigman, Lepe, et al., 1997 #1611 | | | | | | | DBP | | | -11.5 | -9.3 | = 0.010
Roca-Cusachs, Oigman, Lepe, et al., 1997 #1611 | | | | | | | BP control rates at 12 wk (DBP < 90 or decrease in DBP from baseline of ≥ 10 mm Hg): Losartan: 60.0% Captopril: 54.7% p > 0.10 2) Rate of use of a single antihypertensive agent for BP control: NA (no other antihypertensives allowed) 3) Mortality: NR 4) Morbidity: NR 5) Safety:
Roca-Cusachs, Oigman, Lepe, et al., 1997 #1611 | | | | | | | | | Losartan (n=192) | | Captopril (n=204)
Roca-Cusachs, Oigman, Lepe, et al., 1997 #1611 | | | | | | | ≥ 1 clinical AE | | 63 (33%) | | 83 (41%)
Roca-Cusachs, Oigman, Lepe, et al., 1997 #1611 | | | | | | | ≥ 1 drug-related clinical AE | | 20 (10%) | | 27 (13%)
Roca-Cusachs, Oigman, Lepe, et al., 1997 #1611 | | | Losartan | | Captopril | | ≥ 1 serious clinical AE | | 4 (2%) | | 10 (5%)
Roca-Cusachs, Oigman, Lepe, et al., 1997 #1611 | | SBP | 158.2 ± 16.5 | | 157.2 ± 16.7 | | Withdrawn due to clinical AEs | | 5 (3%) | | 12 (6%)
Roca-Cusachs, Oigman, Lepe, et al., 1997 #1611 | | DBP | 103.9 ± 6.5 | | 103.2 ± 7.1 | | ≥ 1 laboratory AE | | 24 (12%) | | 24 (13%)
Roca-Cusachs, Oigman, Lepe, et al., 1997 #1611 | | Concurrent medications (n [%]): Other BP meds not permitted Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria:; - Adult male and female outpatients; - Mild-to-moderate HTN (DBP 90-115 before placebo, then 95-115 after 2 & 4 wks on placebo during run-in; - No concurrent medical conditions; - No therapy that might affect BP; Exclusion criteria:; - Malignant or secondary HTN; - Untreated thyrotoxicosis or hypothyroidism; - Significant cardiovascular, cerebrovascular, hepatic, renal, GI, hematologic, pulmonary, or neurologic disorders; - Uncontrolled diabetes; - Concurrent disease that would preclude participation or survival (e.g., AIDs or neoplasm); - Alcohol or drug abuse; - Clinically significant lab values outside normal range (e.g., serum K < 3.5 or > 5.5 mol/L; - Women who were pregnant or lactating; - Known sensitivity to captopril or other ACEIs; - Concomitant therapy with other investigational drugs, beta-blockers, steroids, ACTH, or lithium | | | | | ≥ 1 drug-related laboratory AE | | 11 (6%)^*^ | | 3 (2%)
Roca-Cusachs, Oigman, Lepe, et al., 1997 #1611 | | | | | | | ^*^p = 0.029; all other between-group comparisons NS Withdrawals for serious clinical AEs included 1 losartan for encephalopathy and HTN crisis, 1 captopril for HA with TIA and hemiparesis. Other withdrawals were “considered unrelated to study treatment.” Withdrawals for clinical AEs included 3 losartan for urticaria + pruritis, chest pain, taste perversion (first 2 related to study treatment); 9 captopril for pruritis, headache (2), vomiting, taste loss, dizziness with headache, rash, dyspnea with heart failure, anxiety with tachycardia (all but last one considered drug-related). Laboratory AEs included: losartan (increased ALT in 4, hyperbilirubinemia in 2, increased serum creatinine in 2, increased BUN in 1, hyperkalemia in 1); captopril (1 drug-related hyperuricemia and 1 hyperkalemia). 6) Specific adverse events:
Roca-Cusachs, Oigman, Lepe, et al., 1997 #1611 | | | | | | | | | Losartan (n = 192) | | Captopril (n = 204)
Roca-Cusachs, Oigman, Lepe, et al., 1997 #1611
Roca-Cusachs, Oigman, Lepe, et al., 1997 #1611 | | | | | | | Headache | | 8% | | 10%
Roca-Cusachs, Oigman, Lepe, et al., 1997 #1611 | | | | | | | Cough | | 6% | | 7%
Roca-Cusachs, Oigman, Lepe, et al., 1997 #1611 | | | | | | | 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: see above 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Rosei, Rizzoni, Muiesan, et al., 2005 #1612 | Geographical location: Italy Study dates: NR Funding source: Takeda Italia Farmeceutici S.p.A., Rome, Italy Interventions:; - Candesartan 8-16 mg (n = 66); - Enalapril 10-20 mg (n = 63); Dose titration/co-interventions: Patients started on lower dose of study drug; moved to higher dose if BP ≥ 130/85 after 6 wk. If BP still uncontrolled after 12 wk, HCTZ 12.5 mg added. If BP not controlled at 18 wk, HCTZ increased to 25 mg. Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: Yes; Was allocation concealment adequate?: NR Baseline/run-in period: 2-wk placebo run-in Duration of treatment: 24 wk Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 129; - Began treatment: 129; - Completed treatment: 118; - Withdrawals/losses to followup: 11; Age: Mean (SD): 58.4 Median: NR Range: 30 to 70 Sex (n [%]): Female: 36% Male: 64% Race/ethnicity (n [%]): NR Baseline blood pressure: Seated trough BP measured after 5-min rest; mean of 3 measurements taken at 1-min intervals BP measured using a mercury sphygmomanometer and a validated automatic device (Omron 705 CP) Baseline mean values NR (from Abstract; see also Figures 1 and 2): Candesartan: 148/90 ± 11/8 mm Hg Enalapril: 148/91 ± 12/8 mm Hg Concurrent medications (n [%]): NR Comorbidities (n [%]): Candesartan/Enalapril: No alcohol: 49%/52% No smoking: 83%/75% Retinopathy: 6%/3% Heart disease: 9%/13% Kidney disease: 2%/3% Recruitment setting: NR Inclusion criteria:; - Grade 1 essential hypertension (SBP 140-159; DBP diastolic 90-99) at the end of 2-wk run-in period; - Age 30-70 yr; - Previous diagnosis of NIDDM with or without hypoglycemic therapy; - Previously treated with antihypertensive drugs (including ACEs or ARBs) for ≤ 1 mo in the 3 mo preceding enrollment; - If previously treated, enrolled only if did not tolerate or respond to previous antihypertensive medication; Exclusion criteria:; - Secondary hypertension; - SBP > 159, DBP > 99; - IDDM, intolerance or contraindications to study drugs; - Use of study drug within 4 wk of enrolment; - Major cardiac arrhythmias, hemodynamically relevant valvular heart disease, AV blocks grade 2 or 3; - CHF (NYHA II-IV); - MI, stroke, coronary surgery, TIA within previous 3 mo; - Angina; - Autonomic neuropathy; - PVD with lesions; - Known renal artery stenosis, kidney transplantation; - Serum creatinine > 1.6 mg/dL; - Severely impaired liver function, serum sodium ≤ 130 mmol/L, serum K ≤ 3.6 mmol/L | | | | | 1) Blood pressure: Mean BP at 24 weeks (from Abstract; not clear whether taken using sphygmomanometer [see Figure 1] or automatic device [see Figure 2]): Candesartan: 132/82 ± 12/7 mm Hg Enalapril: 131/85 ± 14/6 mm/Hg p = NS BP response rates at 24 wk (response not defined): Candesartan: 70.5% Enalapril: 71.9% p = NS 2) Rate of use of a single antihypertensive agent for BP control: Monotherapy at 18-24 weeks: Candesartan: 59% Enalapril: 63.8% 3) Mortality: NR 4) Morbidity: NR 5) Safety: Any AEs: Candesartan: 27/66 (40.9%) Enalapril: 31/63 (49.2%) p = NS 1 non-drug-related serious AE (diabetes decompensation in patient in candesartan group) 6) Specific adverse events: NR 7) Persistence/adherence: Mean compliance: Candesartan: 98.2 ± 13.16% Enalapril: 97.8 ± 13.67% 8) Lipid levels: Triglycerides (mg/dL): | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments:; - Assembly of patients not described; Applicability:; - Patient identification, study site not clear; - All patients had NIDDM
Rosei, Rizzoni, Muiesan, et al., 2005 #1612 | | | | | | | | | Candesartan [underlined: (n = 60)] | | Enalapri [underlined: n = 57)]
Rosei, Rizzoni, Muiesan, et al., 2005 #1612 | | | | | | | Baseline | | 145.5 ± 79.5 | | 143.9 ± 111.5
Rosei, Rizzoni, Muiesan, et al., 2005 #1612 | | | | | | | 24 wk | | 159.1 ± 95.3 | | 154.8 ± 160.5
Rosei, Rizzoni, Muiesan, et al., 2005 #1612 | | | | | | | Total cholesterol (mg/dL):
Rosei, Rizzoni, Muiesan, et al., 2005 #1612 | | | | | | | | | Candesartan [underlined: (n = 60)] | | Enalapri [underlined: (n = 57)]
Rosei, Rizzoni, Muiesan, et al., 2005 #1612 | | | | | | | Baseline | | 212.8 ± 39.4 | | 221.2 ± 37.0
Rosei, Rizzoni, Muiesan, et al., 2005 #1612 | | | | | | | 24 wk | | 210.0 ± 35.4 | | 228.1 ± 37.3
Rosei, Rizzoni, Muiesan, et al., 2005 #1612 | | | | | | | LDL cholesterol (mg/dL):
Rosei, Rizzoni, Muiesan, et al., 2005 #1612 | | | | | | | | | Candesartan [underlined: (n = 60)] | | Enalapri [underlined: (n = 57)]
Rosei, Rizzoni, Muiesan, et al., 2005 #1612 | | | | | | | Baseline | | 142.4 ± 34.8 | | 152.0 ± 35.5
Rosei, Rizzoni, Muiesan, et al., 2005 #1612 | | | | | | | 24 wk | | 140.9 ± 28.8 | | 157.5 ± 34.9
Rosei, Rizzoni, Muiesan, et al., 2005 #1612 | | | | | | | 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: No difference (data not reported) 13) Proteinuria: Candesartan: 33.9 (92.6) Enalapril: 58.3 (195.3)

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Ruff, Gazdick, Berman, et al., 1996 #1614 | Geographical location: 12 centers in the U.S. Study dates: NR Funding source: NR, but authors from Merck Interventions:; - Losartan 50 mg daily; therapy intensified at 2-wk intervals for DBP ≥ 90 (see below) (n = 50); - Enalapril 20 mg daily; therapy intensified at 2-wk intervals for DBP ≥ 90 (n = 25); Titration protocol:; 1. Double dose of study med; 2. Add hctz 25mg daily; 3. Add atenolol 50 mg daily and titrate to 100 mg daily or add dihydropyridine calcium channel blocker; 4. Add other therapy at discretion of investigator; Study design: RCT, parallel-group Blinding:; - Patients: Yes (double-dummy); - Providers: Yes; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: 2- to 7-day baseline washout. No run-in period Duration of treatment: 12 wk Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 75 (2:1 losartan:enalapril); - Began treatment: 75; - Completed treatment: 67; - Withdrawals/losses to followup: 8; Age: Mean (SD): 50.9 (11.6) Median: NR Range: 23-74 Sex (n [%]): Female: 30 (40%) Male: 45 (60%) Race/ethnicity (n [%]): White- 40 (53%) Black- 32 (43%) Hispanic – 2 (3%) Native American – 1 (1%) Baseline blood pressure: Trough seated BP measured using a standard mercury sphygmomano-meter after 5 min rest; average of 3 readings taken at 1-min intervals | | | | | 1) Blood pressure: Seated trough BP: | | | | | | General comments:; - Main limitation is lack of description of numbers screened and eligible; Quality assessment: Overall rating: Good Applicability:; - Exclusion criteria limit the applicability to a larger hypertension population; - Short time frame; - Non-meaningful endpoints beyond BP response and tolerability
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | | Los-pre | | Los-12 wk | Enal -pre | Enal -12 wk
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | SBP | 173.7 (14.5) | | 140.3 (16.1) | 176.5 (14.9) | 133.8 (14.5)
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | DBP | 118 (3.6) | | 90.8 (8.7) | 119 (3.1) | 88.4 (5.1)
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | pre-post differences significant at P < 0.05 Diff in SBP between losart and enal (p = 0.037) Diff in DBP between losart and enal (p = 0.051) BP response: By 12 wk, 98% of losartan patients and 100% of enalapril patients had a DBP < 90 or a reduction of DBP ≥ 10 (between-group difference not significant) Subgroup analysis reported for black vs. non-black. “Similar reductions in black compared with non-black patients” SBP:
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | [underlined: Losartan] | | [underlined: Enalapril] | | | | Non-black | | Black
Ruff, Gazdick, Berman, et al., 1996 #1614 | | SBP | 173.7 ± 14.5 | | 176.5 ± 14.9
Ruff, Gazdick, Berman, et al., 1996 #1614 | | DBP | 118 ± 3.5 | | 119 ± 3.1 | | | | Losart | Enal | Losart | Enal
Ruff, Gazdick, Berman, et al., 1996 #1614 | | Seated response peak BP also collected (5-8 hr after administration) Concurrent medications (n [%]): Antihypertension meds stopped at baseline. No other meds reported. Comorbidities (n [%]): NR Recruitment setting: 12 US centers (no other info) Inclusion criteria:; - Sitting trough DBP 115-130; Exclusion criteria:; - Females of childbearing potential were included only w/ neg preg test w/I 72yrs and monthly thereafter; - DM if fasting sugar >180; - Secondary htn; - Serious heart, liver, or renal disease; - Any other active medical condition or tx that might affect bp or confound results of study; - ASA, acetaminophen, nsaids and low dose TCAs had to be OK'd by study monitor
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | Pre- | | 172.5 (15.4) | 180.3 (15.3) | 175.2 (13.6) | 170.9 (12.9)
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | Post- | | 141.5 (16.8) | 135.4 (14.9) | 138.6 (15.8) | 131.4 (14.2)
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | Change | | -31.0 (16.2) | -44.9 (16.6) | -36.6 (19.5) | -39.5 (20.0)
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | DBP:
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | | | Non-black | | Black
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | | | Losart | Enal | Losart | Enal
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | Pre- | | 118.2 (3.2) | 118.6 (2.5) | 118.9 (3.9) | 120.3 (3.7)
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | Post- | | 91.1 (10.0) | 88.2 (4.4) | 90.5 (6.9) | 88.7 (6.2)
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | Change | | -27.1 (8.9) | -30.4 (4.9) | -28.4 (6.8) | -31.6 (5.0)
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | 2) Rate of use of a single antihypertensive agent for BP control: At week 12: 3/50 in losartan group (6%) 4/25 in enalapril group (16%) 3) Mortality: NR 4) Morbidity: NR 5) Safety:
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | | | Losartan (n = 50) | | Enalapril (n = 25)
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | Adverse event | | 35 (70%) | | 19 (76%)
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | 6/50 pts withdrew from losartan 2/25 pts withdrew from enalapril 6) Specific adverse events:
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | | | Losartan (n = 50) | | Enalapril (n = 25)
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | Headache | | 22% | | 20%
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | Dizziness | | 14% | | 12%
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | Edema | | 4% | | 12%
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | Cough | | 8% | | 12%
Ruff, Gazdick, Berman, et al., 1996 #1614
Ruff, Gazdick, Berman, et al., 1996 #1614 | | | | | | | 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Ruilope, Jager, and Prichard, 2001 #1615 | Geographical location: 48 centers in France, Germany, Ireland, The Netherlands, Spain, Sweden, and UK Study dates: NR Funding source: NR, but contact author employed by Solvay Pharma Interventions:; - Eprosartan 600 mg qd (titrated to 800 mg qd after 3 wk if SBP > 140 mm Hg) (n = 168); - Enalapril 5 mg qd (titrated to 10, then 20 q 3 wk if SBP > 140 mm Hg) (n = 163); Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: Single-blind, placebo run-in 3-4 wks Duration of treatment: 12 weeks Duration of post-treatment followup: 7-10 days after treatment period | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: 396; - Randomized: 334; - Began treatment: 334; - Completed treatment: 290; - Withdrawals/losses to followup: NR; 3 patients had no valid efficacy data and were excluded from analysis; reasons for other discontinuations NR; - Population analyzed = 331 (eprosartan 168, enalapril 163); Age: Mean (SD): 73 Median: NR Range: NR Sex (n [%]): Female: 181 (54%) Male: 153 (46%) Race/ethnicity (n [%]): Caucasian 332 (99%) Baseline blood pressure (± SEM): Trough BP measured 3 times at 2-min intervals after patient seated for at least 5 min using mercury or mercury-calibrated sphygmomano-meter; mean of 3 readings used | | | | | 1) Blood pressure: Mean post-treatment BP values NR Mean changes from baseline (at 12 wk): | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | | | | | | | | | [underlined: Eprosartan] | [underlined: Enalapril] | [underlined: P-value] | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | | | | | | Sit SBP | | | -18.0 | -18.0 | 0.76 | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | | | | | | Sit DBP | | | -9.4 | -9.6 | 0.84 | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | | | | | | Response rates (Sit SBP < 140 or 140-150 with decrease of ≥ 20 mm Hg from baseline; Sit DBP < 90 or 90-100 with decrease of ≥ 10 mm Hg from baseline); last available BP reading used: | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | | | | | | | | [underlined: Eprosartan] | | [underlined: Enalapril] | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | | | | | | SBP | | 68/168 (41%) | | 63/163 (39%) | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | | | | | | DBP | | 108/68 (64%) | | 111/163 (68%) | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | | | | | | 2) Rate of use of a single antihypertensive agent for BP control: Other antihypertensive medication taken during trial: Eprosartan: 8.8% Enalapril: 6.7% 3) Mortality: 2 deaths, one in each group; neither was considered related to study medication 4) Morbidity: NR 5) Safety: | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | | [underlined: Eprosartan] | | [underlined: Enalapril] | | | | [underlined: Eprosartan] | | [underlined: Enalapril] | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | Sit SBP | 176 ± 0.9 | | 175 ± 0.9 | | ≥ 1 AE | | 61 (35.7%) | | 83 (50.9%) | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | Sit DBP | 98 ± 0. | | 98 ± 0.4 | | Susp/prob. AE | | 11 (6.4%) | | 24 (14.7%) | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | Concurrent medications (n [%]): Any medication: Eprosartan: 69% Enalapril: 75.5% Other antihypertensive medication: Eprosartan: 8.8% Enalapril: 6.7% Comorbidities (n [%]): NR Recruitment setting: Not described Inclusion criteria:; - Age ≥ 65 years; - Essential HTN; - Sitting SBP ≥ 160 mmHg and DBP 90-114 mmHg; - Newly diagnosed or requiring change in treatment due to poor efficacy or tolerability; Exclusion criteria:; - Secondary HTN; - Advanced hypertensive retinopathy; - Sitting SBP > 210 mm Hg; - MI or CVA < 90 days; - CHF, angina; - Poorly controlled diabetes; - Significant renal or hepatic disease; - Significant ventricular tachyarrhythmias; - Severe disease (e.g., cancer) which could preclude participation or survival; - Alcohol or drug abuse; - Recent use of investigational drug; - Concurrent use of MAOIs, tricyclics, phenothiazine derivatives, any medication know to affect BP, or sympathomimetic amines | | | | | | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | | | | | | 6) Specific adverse events: | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | | | | | | | | [underlined: Eprosartan] | | [underlined: Enalapril] | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | | | | | | Headache | | 7 (4.1%) | | 10 (6.1%) | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | | | | | | Fatigue | | 5 (2.9%) | | 7 (4.3%) | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | | | | | | Diarrhea | | 5 (2.9%) | | 3 (1.8%) | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | | | | | | Injury | | 4 (2.3%) | | 2 (1.2%) | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | | | | | | Abdominal pain | | 3 (1.8%) | | 4 (2.5%) | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | | | | | | Dizziness | | 3 (1.8%) | | 5 (3.1%) | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | | | | | | Infection viral | | 2 (1.2%) | | 5 (3.1%) | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | | | | | | Coughing | | 1 (0.6%) | | 10 (6.1%) | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | | | | | | UTI | | 0 (0%) | | 5 (3.1%) | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects
Ruilope, Jager, and Prichard, 2001 #1615 | | | | | | | 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | | General comments: None Quality assessment: Overall rating: Good Comments: Enalapril dose not comparable to eprosartan. Applicability:; - Multinational, but virtually all Caucasian subjects

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Saito, Asayama, Ohkubo, et al., 2004 #1616 | Geographical location: Japan (nationwide) Study dates: 2002 - Mar 2003 Funding source: Non-profit foundation, device manufacturers Interventions: CCB (n = 239) ACEI (n = 214) ARB (n = 200) Study design: RCT, parallel-group Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: Yes; Was allocation concealment adequate?: Yes Baseline/run-in period: None Duration of treatment: 6 mo Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: 1736; - Randomized: 1086; - Began treatment: NR; - Completed treatment: 653; - Withdrawals/losses to followup: 433 had not completed ≥ 6 mo followup; Age: Mean (SD): NR Median: NR Range: NR Sex (n [%]): Female: NR Male: NR Race/ethnicity (n [%]): NR (presumably 100% Japanese) Baseline blood pressure: Home BP measured using automated device (Omron HEM-747IC-N) | | | | | 1) Blood pressure: Home values at 6 mo, measured using automated device: | | | | | | General comments:; - BP data from home monitoring, may not be comparable to clinic-based seated measurements; - Rates of discontinuation and switching driven by protocol, rather than usual care, may be more reliable; Quality assessment: Overall rating: Fair Comments:; - Complicated treatment/switching algorithm; - Drug intervention nested within what seems to primarily by a health services intervention; - See above, under General comments; Applicability:; - Japanese ethnic population may not be generalizable to U.S.
Saito, Asayama, Ohkubo, et al., 2004 #1616 | | | | | | | | | [underlined: SBP] | | [underlined: DBP]
Saito, Asayama, Ohkubo, et al., 2004 #1616 | | | | | | | CCB | | 134 ± 12 | | 82 ± 10
Saito, Asayama, Ohkubo, et al., 2004 #1616 | | | | | | | ACEI | | 136 ± 15 | | 80 ± 10
Saito, Asayama, Ohkubo, et al., 2004 #1616 | | | | | | | ARB | | 134 ± 13 | | 80 ± 9
Saito, Asayama, Ohkubo, et al., 2004 #1616 | | | | | | | 2) Rate of use of a single antihypertensive agent for BP control: At 6 months: CCB: 34% (82/239) ACEI: 24% (51/214) ARB: 30% (60/200) 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: At 6 months, switches determined by BP values and computerized treatment algorithm:
Saito, Asayama, Ohkubo, et al., 2004 #1616 | | | | | [underlined: SBP] | [underlined: DBP]
Saito, Asayama, Ohkubo, et al., 2004 #1616 | | CCB | | | 149 ± 14 | 90 ± 10
Saito, Asayama, Ohkubo, et al., 2004 #1616 | | ACEI | | | 150 ± 14 | 89 ± 11
Saito, Asayama, Ohkubo, et al., 2004 #1616 | | ARB | | | 149 ± 13 | 89 ± 10
Saito, Asayama, Ohkubo, et al., 2004 #1616 | | Concurrent medications (n [%]): 0 [0%] Comorbidities (n [%]): NR Recruitment setting: Primary care practice Inclusion criteria:; - Previously untreated patients ≥ 40 years of age; - Home BP values ≥ 135/85 mmHg; Exclusion criteria: NR
Saito, Asayama, Ohkubo, et al., 2004 #1616
Saito, Asayama, Ohkubo, et al., 2004 #1616 | | | | | | | Drug | | | Continued | Switched | D/c'd
Saito, Asayama, Ohkubo, et al., 2004 #1616
Saito, Asayama, Ohkubo, et al., 2004 #1616 | | | | | | | ARB | | | 89% | 9% | 2%
Saito, Asayama, Ohkubo, et al., 2004 #1616
Saito, Asayama, Ohkubo, et al., 2004 #1616 | | | | | | | ACEI | | | 71% | 28% | 1%
Saito, Asayama, Ohkubo, et al., 2004 #1616
Saito, Asayama, Ohkubo, et al., 2004 #1616 | | | | | | | CCB | | | 89% | 8% | 3%
Saito, Asayama, Ohkubo, et al., 2004 #1616
Saito, Asayama, Ohkubo, et al., 2004 #1616 | | | | | | | 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Sanchez, Masnatta, Pesiney, et al., 2008 #1200 | Geographical location: Buenos Aires, Argentina Study dates: NR Funding source: NR Interventions:; - Ramipril 10 mg daily (n = 34); - Telmisartan 80 mg daily (n = 34); Were additional anti-hypertension medications allowed: No Study design: RCT, crossover Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: No; Was allocation concealment adequate?: NR Baseline/run-in period: 2 weeks Washout period(s): 2 weeks Duration of treatment: 3 months (and then 3 months after washout and crossover) Duration of post-treatment followup: None | Number of patients: N = 34; - Screened for inclusion: 42; - Eligible for inclusion: 34; - Randomized: 34; - Began treatment: 34; - Completed treatment: 34; - Withdrawals/losses to followup: 0; Age: Mean (SD): NMHT 32 ± 5 MHT 34 ± 4 NMHT = non-modulating hypertensive MHT = modulating hypertensive Sex (n [%]): Female: 15 (44.1%) Male: 19 (55.9%) Race/ethnicity (n [%]): NR Baseline blood pressure: Blood pressure values were the mean value of three consecutive measurements, elapsed by 1 min, performed in each patient at the end of each of the above conditions. Ramipril: NMHT 162 ± 12, 97 ± 4 MHT 159 ± 10, 102 ± 4 Telmisartan NMHT 161 ± 9, 96 ± 5 MHT 154 ± 8, 96 ± 5 Concurrent non-hypertension medications (n [%]): None allowed Comorbidities (n [%]): NR Recruitment setting: Outpatient clinic Inclusion criteria:; - Essential HTN seen in the outpatient clinic; - Normal renal function; Exclusion criteria:; - Secondary HTN (by history and physical examination, screening biochemical testing, renal echography and nuclear resonance or renal arteriography); - Failure to complete 10-day period of salt intake or in compliance to the daily sodium intake | | | | | 1) Blood pressure: 3 months: Ramipril: NMTH 139 ± 7, 89 ± 2 MTH 142 ± 6, 93 ± 3 Telmisartan: NMTH 137 ± 5, 86 ± 3 MTH 137 ± 6, 88 ± 4 All were p < 0.05 compared to baseline Article states that SBP and DBP were similarly reduced by the two interventions 2) Rate of use of a single antihypertensive agent for BP control: 100% 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: Telmisartan improved the triglyceride level in both MHT and NMHT patients compared with both baseline values and ramipril 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: In MHT patients, after 3 months treatment with either ramipril or telmisartan no changes were found in fasting and 120min glycemia or insulemia In NMHT patients, telmisartan after 3 months treatment significantly reduced fasting and 120 min insulinemia (fasting 8.4 ± 2, 120 min 25 ± 10 uU% p < 0.01) compared to either baseline values or ramipril treatment Telmisartan improved the HOMA-IR index in both MHT and NMHT patients compared with both baseline values and ramipril 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | | General comments: Comparison of treatment focused on high renin nonmodulating salt-sensitive hypertensives Quality assessment: Overall rating: Fair Comments:; - Randomized; - Complete followup of all enrolled patients; - Similar treatment for 2 interventions other than medication; - Objective outcomes (except maybe BP) done rigorously; - Not blinded; - Baseline characteristics not reported for telmisartan vs. ramipril groups; Applicability: Focuses on NMHT versus MHT patients

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Sato, Tabata, Hayashi, et al., 2003 #1617 | Geographical location: Ibaraki, Japan Study dates: NR Funding source: NR Interventions: Cross sectional cohort of patients treated with:; - Trandolapril (n = 18); - Enalapril (n = 5) or; - Candesartan (n = 26); If BP not controlled (< 130/85 mm Hg), then calcium antagonist, α1-blocker, and central-acting α2-stimulant added successively Study design: Cross-sectional cohort study Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: No; Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: NA (patients were treated previously with ACEI or ARB for 11 ± 3 months) Duration of post-treatment followup: NA | Number of patients: 49 (cross-sectional cohort) Age: Mean (SD): 63.3 Median: NR Range: NR Sex (n [%]): Female: 23 (47%) Male: 26 (53%) Race/ethnicity (n [%]): NR Baseline blood pressure: Seated BP measured using a mercury sphygmomanometer after 15-min rest (average of 3 readings) Note: 15/49 patients (30.6%) normotensive Mean baseline BP values: | | | | | 1) Blood pressure: NR separately for hypertensive patients 2) Rate of use of a single antihypertensive agent for BP control: NR separately for hypertensive patients 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: ACEI: cough 2 patients No other clinical AEs observed 7) Persistence/adherence: NR 8) Lipid levels: NR separately for hypertensive patients 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR separately for hypertensive patients 11) LV mass/function: NR (LVMI not reported by treatment/hypertension status) 12) Creatinine/GFR: NR separately for hypertensive patients 13) Proteinuria: Mean changes in urinary albumin excretion (± SEM, mg/g creatinine), hypertensive patients only: | | | | | | General comments:; - 15/49 subjects (30.6%) were normotensive; limited results reported separately for hypertensive subjects; Quality assessment: Overall rating: Poor Comments:; - Results not separated by hypertension status; - Cross-sectional without establishment of an inception cohort; Applicability:; - Limited to a single hospital in Japan; - All patients had diabetic nephropathy stage 2 or 3A
Sato, Tabata, Hayashi, et al., 2003 #1617 | | | | | [underlined: ACEI] | [underlined: ARB] | | | [underlined: ACEI (n = 16)] | | [underlined: ARB (n = 18)]
Sato, Tabata, Hayashi, et al., 2003 #1617 | | SBP | | | 141 ± 13 | 142 ± 16 | Before | | 417 ± 162 | | 455 ± 166
Sato, Tabata, Hayashi, et al., 2003 #1617 | | DBP | | | 78 ± 11 | 79 ± 9 | After | | 92 ± 37 | | 99 ± 52
Sato, Tabata, Hayashi, et al., 2003 #1617 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): See Inclusion criteria Recruitment setting: Single hospital Inclusion criteria:; - Clinical diagnosis of diabetic nephropathy stage 2 or 3A (defined by presence of either micro-albuminuria with urinary albumin excretion [UAE] 30-300 mg/g creatinine [stage 2] or overt proteinuria [UAE > 300 mg/g creatinine] with a glomerular filtration rate > 60 mL/min [stage 3A]); Exclusion criteria: None specified

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Scaglione, Argano, Di Chiara, et al., 2007 #214 | Geographical location: Palermo, Italy Study dates: NR Funding source: Project grant (60%) from University of Palermo (Italy) Interventions:; - Losartan 50 mg/day (n = 19); - Ramipril 5 mg/day (n = 19); - Combination of losartan 50 mg/day plus ramipril 5 mg/day (n = 19); Were additional anti-hypertension medications allowed: Yes If Yes to above, was this done: Per protocol: HCTZ (12.5 mg once daily) was added to achieve BP < 140/90 (3 total, one per group) Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: Yes; Was allocation concealment adequate?: Yes Baseline/run-in period: NA Duration of treatment: 24 weeks Duration of post-treatment followup: NA | Number of patients: N = 57; - Screened for inclusion: 328 consecutive hypertensive patients; - Eligible for inclusion: NR; - Randomized: 57; - Began treatment: 57; - Completed treatment: 57; - Withdrawals/losses to followup: 0; Age: Mean (SD): 55.67 (7.34) Sex (n [%]): Female: 27 (47.4%) Male: 30 (52.6%) Race/ethnicity (n [%]): NR Baseline blood pressure: SBP/DBP: Losartan: 162 ± 7/94 ± 6 Ramipril: 159 ± 7/98 ± 9 Combo: 161 ± 8/94 ± 12 Sitting BP was measured three times with an interval of about 2 min, and the mean was calculated Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: Antihypertensive centre of the Department of Internal Medicine, University of Palermo (Italy) Inclusion criteria: SBP 140-179 mmHg and/or DBP 90-109 mmHg Exclusion criteria:; - Any form of secondary hypertension; - Stage III essential hypertension; - Any irreversible end organ damage owing to arterial hypertension; - Metabolic bone disease; - Hyperthyroidism; - Cardiovascular disease; - Diabetes; - Dyslipidemia; - Hepatic disease; - Alcoholic liver disease; - Malignancy | | | | | 1) Blood pressure: | | | | | | General comments:; - Small study; - Stratified (matched) randomization; - Complete followup on all patients; - ITT analysis; - Groups similar at baseline and treated similarly; Quality assessment: Overall rating: Good Applicability:; - Small trial in Italy recruiting from hypertension center; - Other BP drugs and comorbidities either not allowed or not reported
Scaglione, Argano, Di Chiara, et al., 2007 #214 | | | | | | | | | | [underlined: Losart] | [underlined: Rami] | [underlined: Comb]
Scaglione, Argano, Di Chiara, et al., 2007 #214 | | | | | | | SBP, mmHg | | | 133 ± 5^*^ | 134 ± 5^*^ | 131 ± 6^*^
Scaglione, Argano, Di Chiara, et al., 2007 #214 | | | | | | | DBP, mm Hg | | | 82 ± 7^*^ | 81± 8^*^ | 78 ± 8^*^
Scaglione, Argano, Di Chiara, et al., 2007 #214 | | | | | | | ^*^P < 0.05 vs. baseline
Scaglione, Argano, Di Chiara, et al., 2007 #214 | | | | | | | | | | [underlined: Losart] | [underlined: Rami] | [underlined: Comb]
Scaglione, Argano, Di Chiara, et al., 2007 #214 | | | | | | | TGFb1 (ng/ml) | | | 4.1 ± 4.8 | 3.1 ± 3.1 | 6 ± 3.4^*^†
Scaglione, Argano, Di Chiara, et al., 2007 #214 | | | | | | | DTGFb1 (%) | | | 48 ± 28 | 42 ± 29 | 80 ± 12^*^†
Scaglione, Argano, Di Chiara, et al., 2007 #214 | | | | | | | ΔLVM/h^2.7^ (g/m^2.7^) | | | 6.4 ± 5 | 8.5 ± 8.5 | 14 ± 7‡§
Scaglione, Argano, Di Chiara, et al., 2007 #214 | | | | | | | ΔLVM/h^2.7^ (%) | | | 14 ± 9 | 16 ± 16 | 24 ± 15‡§
Scaglione, Argano, Di Chiara, et al., 2007 #214 | | | | | | | ΔSBP (mm Hg) | | | 29 ± 9 | 25 ± 12 | 30 ± 11
Scaglione, Argano, Di Chiara, et al., 2007 #214 | | | | | | | ΔSBP (%) | | | 18 ± 5 | 16 ± 7 | 19 ± 6
Scaglione, Argano, Di Chiara, et al., 2007 #214 | | | | | | | ΔDBP (mm Hg) | | | 14 ± 9 | 17 ± 11 | 17 ± 12
Scaglione, Argano, Di Chiara, et al., 2007 #214 | | | | | | | ΔDBP (%) | | | 14 ± 11 | 18 ± 10 | 17 ± 12
Scaglione, Argano, Di Chiara, et al., 2007 #214 | | | | | | | ΔMBP (mm Hg) | | | 16 ± 8 | 18 ± 9 | 21 ± 11
Scaglione, Argano, Di Chiara, et al., 2007 #214 | | | | | | | ΔMBP (%) | | | 14 ± 7 | 15 ± 7 | 18 ± 8
Scaglione, Argano, Di Chiara, et al., 2007 #214 | | | | | | | ^*^P < 0.03 vs. losartan †P < 0.0001 vs. ramipril ‡P< 0.05 vs. losartan §P < 0.03 vs. ramipril
Scaglione, Argano, Di Chiara, et al., 2007 #214 | | | | | | | Patients with LVH at baseline:
Scaglione, Argano, Di Chiara, et al., 2007 #214 | | | | | | | | | | [underlined: Losart] | [underlined: Rami] | [underlined: Comb]
Scaglione, Argano, Di Chiara, et al., 2007 #214 | | | | | | | DLVM/h^2.7^ (%) | | | -16 ± 4 | -19 ± 5 | -27 ± 5†‡
Scaglione, Argano, Di Chiara, et al., 2007 #214 | | | | | | | †P < 0.02 vs. ramipril; ‡P < 0.01 vs. losartan
Scaglione, Argano, Di Chiara, et al., 2007 #214 | | | | | | | 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: See immediately below 6) Specific adverse events: “Two patients complained of asthenia, two of cough and three of dizziness but treatments were not discontinued.” (treatment assignments NR) 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: See table under outcome 1, above 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Schieffer, Bunte, Witte, et al., 2004 #1618 | Geographical location: Hanover and Hamburg, Germany Study dates: NR Funding source: Sanofi-Synthelabo Interventions:; - Enalapril 2 × 10 mg/day (gp A, ENAL) (n = 27); - Irbesartan 2 × 150 mg/day (gp B, IRB) (n = 21); Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: NR; Was allocation concealment adequate?: Yes (randomization list) Baseline/run-in period: NA Duration of treatment: 3 months Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: 60; - Eligible for inclusion:; - Randomized: 48; - Began treatment: 48; - Completed treatment: 47; - Withdrawals/losses to followup: 1 (enalapril; symptomatic hypotension); a further 11 patients were excluded from the analysis due to protocol violations; Age: Mean (SD): 57.1 (weighted average) Median: NR Range: NR Sex (n [%]): Female: 12 Male: 36 Race/ethnicity (n [%]): NR Baseline blood pressure: | | | | | 1) Blood pressure: At 3 months (method of assessment NR): | | | | | | General comments: None Quality assessment: Overall rating: Poor Comments:; - Not clear all patients were hypertensive; - No run-in period; - LV results not quantified; Applicability:; - Race of patients not described
Schieffer, Bunte, Witte, et al., 2004 #1618 | | | | | | | | | [underlined: Enalapril] | | [underlined: Irbesartan]
Schieffer, Bunte, Witte, et al., 2004 #1618 | | | | | | | SBP: | | 133 ± 19^*^ | | 133 ± 22^*^
Schieffer, Bunte, Witte, et al., 2004 #1618 | | | | | | | DBP: | | 83 ± 9^**^ | | 80 ± 12^**^
Schieffer, Bunte, Witte, et al., 2004 #1618 | | | | | | | ^*^p < 0.01 vs. baseline ^**^p < 0.05 vs. baseline
Schieffer, Bunte, Witte, et al., 2004 #1618 | | | | | | | 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: Reported to be no difference between groups (no numerical data reported) 12) Creatinine/GFR: NR 13) Proteinuria: NR
Schieffer, Bunte, Witte, et al., 2004 #1618 | | | | | [underlined: Enalapril] | [underlined: Irbesartan]
Schieffer, Bunte, Witte, et al., 2004 #1618 | | SBP: | | | 147 ± 35 | 143 ± 23
Schieffer, Bunte, Witte, et al., 2004 #1618 | | DBP: | | | 88 ± 16 | 84 ± 16
Schieffer, Bunte, Witte, et al., 2004 #1618 | | Method of assessment NR Concurrent medications (n [%]): 1 patient in each group received oral diabetes medication Comorbidities (n [%]): 4 patients receiving irbesartan and 6 receiving enalapril had diabetes Recruitment setting: NR (university hospital?) Inclusion criteria:; - 6-8 weeks after coronary angioplasty; - No symptoms of angina or heart failure; Exclusion criteria:; - Receiving ACE, ARB, HMG-CoA reductase inhibitor, NSAID (100 mg aspirin allowed); - CRF; - LDL ser levels >150mg/dL; - Hypotension (SBP < 90mm)

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Schram, van Ittersum, Spoelstrade Man, et al., 2005 #1619 | Geographical location: 6 sites in The Netherlands Study dates: July 1998-Oct 2001 Funding source: AstraZeneca Interventions:; - HCTZ 12.5 mg (n = 24); - Candesartan 8 mg (n = 24); - Lisinopril 10 mg (n = 22); Dose titration/co-interventions: Target BP = seated BP < 130/85 or SBP decrease > 10% with DBP < 85. If target BP not achieved, then following added consecutively:; - HCTZ 12.5 mg; - Doubling of study medication; - Felodipine 5 mg; - Metoprolol 50 mg; - Doxazosin 2 mg; - Felodipine 5 mg; - Metoprolol 50 mg; - Doxazosin 2 mg; - Felodipine 5 mg; - Metoprolol 100 mg; - Doxazosin 4 mg; Study design: RCT, parallel-group Blinding:; - Patients: Yes (double-dummy); - Providers: Yes; - Assessors of outcomes: Yes; Was allocation concealment adequate?: NR Baseline/run-in period: 1-mo run-in (patients treated with diet only); if on ACEIs, these were withdrawn for 3 months prior to the run-in period Duration of treatment: 4- to 6-mo BP titration period (continued until target BP achieved or until above treatment protocol exhausted), 12-mo study period Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 70; - Began treatment: 70; - Completed treatment: 60; - Withdrawals/losses to followup: 10 (9 due to AEs, 1 for unspecified reasons); Age (candesartan and lisinopril groups): Mean (SD): 61.0 Median: NR Range: NR Sex (candesartan and lisinopril groups; n [%]): Female: 27/46 (59%) Male: 19/46 (41%) Race/ethnicity (n [%]): 100% Caucasian Baseline blood pressure: Seated BP measured after 5 min of seated rest; mean of 3 consecutive measurements) | | | | | 1) Blood pressure: Mean seated BP at 12 mo: | | | | | | General comments:; - Comparatively complicated treatment protocol with multiple co-interventions (“aggressive antihypertensive therapy”); - Pre-study titration phase lasted until target BP achieved or until treatment options exhausted (4-6 mo); Quality assessment: Overall rating: Good Applicability:; - No mention of site selection; not clear if all sites were hospital-based clinics; - All patients had type 2 diabetes; - 100% Caucasian study population
Schram, van Ittersum, Spoelstrade Man, et al., 2005 #1619 | | | | | | | | | Candesartan (n = 24) | | Lisinopril (n = 22)
Schram, van Ittersum, Spoelstrade Man, et al., 2005 #1619
Schram, van Ittersum, Spoelstrade Man, et al., 2005 #1619 | | | | | | | SBP | | 133 ± 15 | | 132 ± 12
Schram, van Ittersum, Spoelstrade Man, et al., 2005 #1619 | | | | | | | DBP | | 81 ± 11 | | 80 ± 7
Schram, van Ittersum, Spoelstrade Man, et al., 2005 #1619 | | | | | | | p = NS for between-group differences Percentage of patients achieving target BP (seated BP < 130/85 or SBP decrease > 10% with DBP < 85) after titration phase: Candesartan: 67% Lisinopril: 68% 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: None 4) Morbidity: NR 5) Safety: Withdrawals due to AEs: Candesartan: 3/24 (12.5%) Lisinopril: 1/22 (4.5%) AEs leading to withdrawal: Candesartan: Palpitations 1; dizziness 1; microalbuminuria 1 Lisinopril: Rise in creatinine 1 6) Specific adverse events: NR except AEs leading to withdrawal (see immediately above) 7) Persistence/adherence: NR 8) Lipid levels: No change (data not shown) 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: No change in HbA1c (data not shown) 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: Urinary albumin excretion decreased significantly at 12 mo vs. baseline in both groups, with no significant difference between groups (data shown only graphically [Figure 3])
Schram, van Ittersum, Spoelstrade Man, et al., 2005 #1619 | | | | | Candesartan (n = 24) | Lisinopril (n = 22)
Schram, van Ittersum, Spoelstrade Man, et al., 2005 #1619
Schram, van Ittersum, Spoelstrade Man, et al., 2005 #1619 | | SBP | | | 151± 14 | 149 ± 9
Schram, van Ittersum, Spoelstrade Man, et al., 2005 #1619 | | DBP | | | 94 ± 10 | 93 ± 7
Schram, van Ittersum, Spoelstrade Man, et al., 2005 #1619 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: Outpatient clinics, newspaper advertisements Inclusion criteria:; - Type II diabetes mellitus for ≥ 6 mo; - Age 35 to 70 yr; - Caucasian ethnicity; - Urinary albumin excretion < 100 mg/24 hr; Exclusion criteria:; - Pregnancy or planned pregnancy; - History of MI, angina, coronary artery bypass surgery, angioplasty, stroke, CHF, malignancy, or other serious illness; - Serum creatinine > 140 μmol/L; - BMI > 35 kg/m^2^; - Alcohol and/or drug abuse; - Participation in other clinical trials

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Sengul, Altuntas, Kurklu, et al., 2006 #291 | Geographical location: Istanbul, Turkey Study dates: NR Funding source: NR Interventions: Phase I (weeks 1-24); 1. Telmisartan 80 mg; 2. Lisinopril 20 mg; Phase II (weeks 24-52); 1. Telmisartan 80 mg; 2. Lisinopril 20 mg; 3. Telmisartan 80 mg + lisinopril 20 mg; 4. Lisinopril 20mg + telmisartan 80mg; Were additional anti-hypertension medications allowed: Yes If Yes to above, was this done: Per protocol Study design: RCT, parallel-group (authors call it “crossover”, but they simply add a med for half of each of the 1^st^ 2 treatment groups) Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: 2 weeks Washout period(s): No washout during addition of 2^nd^ agent after 24 weeks Duration of treatment: 24 weeks phase I (ACE vs. ARB) + 28 weeks phase II (ACE vs. ARB vs. ACE + ARB); total > 52 weeks Duration of post-treatment followup: NR | Number of patients: Weeks 1-24: N = 219 Weeks 24-52: N = 192; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 219; - Began treatment: 219; - Completed treatment: 192; - Withdrawals/losses to followup: 27; Age: Mean (SD): Weeks 1-24: 56.6 ± 8.3 Weeks 24-52: 56.9 ± 8.1 Range: 40-65 Sex (n [%]): Female: Weeks 1-24: 137 (62.6%) Weeks 24-52: 119 (62.0%) Male: Weeks 1-24: 82 (37.4%) Weeks 24-52: 73 (38.0%) Race/ethnicity (n [%]): NR Baseline blood pressure: Assessment: “SBP and DBP were measured in the morning about 24 h after the previous drug administration (trough value) using an automatic device (Omron HEM-705 CP, Omron Electronics, Tokyo, Japan) with the patient having been seated for 10 min. The mean of the three measurements taken at 5-min intervals was recorded. Blood pressure was also measured once after the patient had been standing for 2 min.” Phase I (weeks 1-24): n = 109, 110, respectively | | | | | 1) Blood pressure: Phase I (Weeks 1-24): | | | | | | General comments: Unusual design, but 2 phases allow comparison of ACEI vs. ARB, then longer evaluation of ACEI vs. ARB vs. ACEI/ARB vs. ARB/ACEI. Quality assessment: Overall rating: Fair Comments:; - Protocol/measurements clear; - Randomization not discussed; - Open-label and blinding of measurements not clear; Applicability:; - All diabetes population with history of microalbuminuria; - Turkish population
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | | | | | | | | | [underlined: Telmisartan] | [underlined: Lisinopril] | [underlined: p value]
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | | | | | | SBP: | | | -10.0 | -11.1 | p > 0.2
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | | | | | | DBP: | | | -5.3 | -5.6 | p > 0.2
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | | | | | | Phase II (Weeks 24-52):
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | | | | | | | [underlined: Telm] | [underlined: Lisin] | [underlined: Telm+Lis] | [underlined: Lis+Telm] | [underlined: p]
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | | | | | | SBP: | -15.1 | -16.4 | -25.5 | -25.2 | 0.003
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | | | | | | DBP: | -10.2 | -10.4 | -15.4 | -15.2 | 0.003
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | | | | [underlined: Telmisartan] | [underlined: Lisinopril] | 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: 15 discontinued lisinopril due to AEs: nausea, stomach upset, respiratory infection, cough, headache, dizziness/feeling weak 12 discontinued telmisartan due to AEs: nausea, headache, dizziness, stomach upset, cough, GI problems, withdrawal of consent 6) Specific adverse events: See above 7) Persistence/adherence: Collected but NR, apart from discontinuations due to AEs 8) Lipid levels: Measurements: “High-density lipoprotein cholesterol was measured by a precipitation-based method with phosphotungstic acid. Low-density lipoprotein cholesterol was calculated using Friede- wald's formula.” Serum LDL cholesterol (mg/dL; ranges available if needed for meta-analyses):
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | SBP: | | | 150.4 ± 14.2 | 151.2 ± 14.4 | | | [underlined: Baseline] | | [underlined: 52 weeks]
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | DBP: | | | 89.9 ± 5.4 | 87.9 ± 5.2 | Telmisartan | | 3.4 | | 3.6
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | Phase II (weeks 24-52): n = 48, 48, 49, 47, respectively | | | | | Lisinopril | | 3.3 | | 3.5
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | | | | [underlined: Telmisartan] | [underlined: Lisinopril] | Telm + Lisin | | 3.5 | | 3.5
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | SBP: | | | 140.4 ± 14.0 | 140.1 ± 13.2 | Lisin + Telm | | 3.5 | | 3.4
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | DBP: | | | 84.6 ± 7.0 | 82.3 ± 6.6 | ^*^p = 0.42 at baseline and p = 0.40 at 52 weeks
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | | | | Telm + Lisin | Lisin + Telm | Serum triglycerides (mmol/L; ranges available if needed for meta-analyses):
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | SBP: | | | 140.2 ± 13.4 | 139.5 ± 13.0 | | | [underlined: Baseline] | | [underlined: 52 weeks]
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | DBP: | | | 83.4 ± 6.7 | 82.0 ± 6.5 | Telmisartan | | 2.2 | | 2.4
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | Concurrent non-hypertension medications (n [%]): | | | | | Lisinopril | | 2.4 | | 2.4
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | Phase I (Weeks 1-24): | | | | | Telm + Lisin | | 2.3 | | 2.5
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | | | | [underlined: Telmisartan] | [underlined: Lisinopril] | Lisin + Telm | | 2.2 | | 2.4
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | HCTZ | | | n = 19 | n = 21 | ^*^p = 0.43 at baseline and p = 0.40 at 52 wks
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | 12.5 mg/d Phase II (Weeks 24-52): | | | | | 9) Progression to type 2 diabetes: NA 10) Markers of carbohydrate metabolism/diabetes control: Authors state “no significant changes in mean values for HgbA1c” 11) LV mass/function: NR 12) Creatinine/GFR: Serum creatinine (mmol/L; [95% CI available if needed for meta-analyses; as well as creatinine clearance calculated by the Cockcroft-Gault formula)
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | | | | [underlined: Telmisartan] | [underlined: Lisinopril] | | | [underlined: Baseline] | | [underlined: 52 weeks]
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | HCTZ | | | n = 1 | n = 10 | Telmisartan | | 85 | | 82
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | 12.5 mg/d | | | | | Lisinopril | | 86 | | 83
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | | | | [underlined: Telm + Lisin] | [underlined: Lisin + Telm] | Telm + Lisin | | 84 | | 84
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | HCTZ | | | n = 7 | n = 8 | Lisin + Telm | | 83 | | 83
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | Comorbidities (n [%]): Diabetes 2 n=219 (100%) Recruitment setting: NR – appears to be single academic center, Istanbul, Turkey Inclusion criteria:; - Previous diagnosis of HTN (SBP ≥ 140 mmHg or DBP ≥ 90 mmHg), despite receiving ACE inhibitor monotherapy for ≥ 6 months; - Microalbuminuria (AER rate 30-300 mg/24 hr for a minimum of 3 consecutive occasions; Exclusion criteria:; - Type 1 DM; - Alcoholism; - Thyroid disease; - SBP > 200 mmHg; - Any non-diabetic cause of secondary HTN; - Urinary tract infection; - Persistent haematuria; - Chronic liver disease; - Overt carcinoma; - Any cardiovascular event in the previous 6 months; - Serum creatinine ≥ 150 mmol/L; - Serum potassium ≥ 5.5 mmol/L; - Pregnancy
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | | | | | | ^*^p = 0.41 at baseline and p = 0.35 at 52 wks 13) Proteinuria: Reduction in abumin excretion rate (AER), measured in mg/24hr: “Microalbuminuria was determined using turbidimetry (Cobas Mira Plus, Roche, Montclaire, NJ, USA) as the geometric mean of AER of three consecutive 24-h urine collections.” (95% CI available if needed for meta-analyses.) Phase I (Weeks 1-24):
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | | | | | | | | | [underlined: Telmisartan] | [underlined: Lisinopril] | [underlined: p value]
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | | | | | | AER: | | | -80 | -98 | 0.12
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | | | | | | Phase II (Weeks 24-52):
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | | | | | | | [underlined: Telm] | [underlined: Lisin] | [underlined: Telm+Lis] | [underlined: Lis+Telm] | [underlined: p]
Sengul, Altuntas, Kurklu, et al., 2006 #291 | | | | | | | AER: | -92 | -107 | -136 | -139 | 0.04

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Shand, 2000 #1620 and Shand and Lynn, 2000 #1621 | Geographical location: Christchurch, New Zealand Study dates: NR Funding source: Merck Sharp and Dohme Interventions:; - Losartan 50-100 mg daily (n = 15); - Enalapril 2.5-10 mg daily (n = 14 ); Dose titration/co-interventions: Both drugs titrated at discretion of treating MD/investigator Study design: RCT, parallel-group Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: No; Was allocation concealment adequate?: NR Baseline/run-in period: 14-day washout of previous antihypertensive meds; no other run-in Duration of treatment: 120 days Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 29; - Began treatment: 29; - Completed treatment: 27; - Withdrawals/losses to followup: 2 withdrawals; Age: Mean (SD): 45 (13) Median: NR Range: NR Sex (n [%]): Female: 14 (48%) Male: 15 (52%) Race/ethnicity (n [%]): NR Baseline blood pressure: Seated BP measured using a standard mercury sphygmomano-meter; median of 3 readings | | | | | 1) Blood pressure: Mean seated BP (SD): | | | | | | General comments:; - One patient in the losartan group was excluded from analysis due to ineffective BP control; Quality assessment: Overall rating: Poor Comments:; - Ill-defined protocol; - Not blinded; - Missing information; - Large BP differences in treatment groups at baseline (suggesting failure of randomization); Applicability:; - Source of participants and recruitment not described; - No information on AEs; - All patients had renal parenchymal disease
Shand, 2000 #1620 and Shand and Lynn, 2000 #1621
Shand, 2000 #1620 and Shand and Lynn, 2000 #1621 | | | | | | | | | Losart Pre- | Losart 120 days | Enal Pre- | Enal 120 days
Shand, 2000 #1620 and Shand and Lynn, 2000 #1621
Shand, 2000 #1620 and Shand and Lynn, 2000 #1621 | | | | | | | SBP | | 153 (18) | 138 (16) | 141 (14) | 134 (10)
Shand, 2000 #1620 and Shand and Lynn, 2000 #1621
Shand, 2000 #1620 and Shand and Lynn, 2000 #1621 | | | | | | | DBP | | 100 (13) | 88 (8) | 96 (13) | 87 (10)
Shand, 2000 #1620 and Shand and Lynn, 2000 #1621
Shand, 2000 #1620 and Shand and Lynn, 2000 #1621 | | | | | [underlined: Losartan] | [underlined: Enalapril] | P < 0.01 for losartan SBP and DBP pre-/post- P < 0.01 for enalapril DBP pre-/post- (not SBP) 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: Generally not reported. 1 patient withdrew from enalapril arm due to cough. No other AEs reported. 6) Specific adverse events: NR except AEs leading to withdrawal (see immediately above) 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: Mean creatinine clearance (mL/sec 1.73 m^2^):
Shand, 2000 #1620 and Shand and Lynn, 2000 #1621 | | SBP | | | 153 ± 18 | 141 ± 14 | | | [underlined: Losartan] | | [underlined: Enalapril]
Shand, 2000 #1620 and Shand and Lynn, 2000 #1621 | | DBP | | | 100 ± 13 | 96 ± 13 | Baseline | | 1.88 (0.32) | | 1.82 (0.21)
Shand, 2000 #1620 and Shand and Lynn, 2000 #1621 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria:; - Hypertension; - Renal parenchymal disease; - Stable renal function; Exclusion criteria:; - Patients on diuretics at baseline; - Require > 1 med for BP control at baseline | | | | | 120 days | | 1.90 (0.32) | | 1.69 (0.21)
Shand, 2000 #1620 and Shand and Lynn, 2000 #1621 | | | | | | | Mean plasma creatinine (mmol/L):
Shand, 2000 #1620 and Shand and Lynn, 2000 #1621 | | | | | | | | | [underlined: Losartan] | | [underlined: Enalapril]
Shand, 2000 #1620 and Shand and Lynn, 2000 #1621 | | | | | | | Baseline | | 0.11 (0.05) | | 0.11 (0.04)
Shand, 2000 #1620 and Shand and Lynn, 2000 #1621 | | | | | | | 120 days | | 0.11 (0.06) | | 0.11 (0.05)
Shand, 2000 #1620 and Shand and Lynn, 2000 #1621 | | | | | | | 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Shibasaki, Masaki, Nishiue, et al., 2002 #1622 | Geographical location: Osaka, Japan Study dates: Nov 1998 – April 2000 Funding source: Ministry of Education, Science, Sports, and Culture - Japan Interventions: Number of patients randomized to each treatment group NR; - Losartan 50 mg daily (n = 10 completed); - Amlodipine 5 mg daily (n = 10 completed); - Enalapril 5 mg daily (n = 10 completed); No dose titration or co-interventions Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: Yes; Was allocation concealment adequate?: NR Baseline/run-in period: 2 wk (intervention not described) Duration of treatment: 6 mo Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: 45; - Eligible for inclusion: 38; - Randomized: 38; - Began treatment: 38; - Completed treatment: 30; - Withdrawals/losses to followup: 8; Age: Mean (SD): 55 (3) Median: NR Range: 21-80 Sex (n [%]): Female: 11 (37%) Male: 19 (63%) Race/ethnicity (n [%]): NR - presume all native Japanese Baseline blood pressure: Supine pre-dialysis (only mean BP reported); measured using mercury sphygmomanometer Baseline mean BP (SD) reported for n = 30 completers: Losartan: 101.5 (4) Enalapril: 101.2 (3.3) Amlodipine: 99.3 (2.2) Concurrent medications (n [%]): NR Comorbidities (n [%]): Diabetes: Total - 12/30 (40%) Each group had 4/10 (40%) Recruitment setting: Single dialysis center in Osaka, Japan Inclusion criteria:; - Uremia referred for dialysis; - On maintenance dialysis for at least 1 mo; - Maintained stable post-dialysis weight; - SBP > 150 or DBP > 90; Exclusion criteria:; - History of ischemic heart disease; - History of CVA; - Inadequate echocardiogram for LV mass; - Atrial fibrillation; - Recurrent CHF; - Significant valvular heart disease; - Nephritic syndrome; - History of neoplasia | | | | | 1) Blood pressure: Mean BP, supine and pre-dialysis (seated values, supine SBP and DBP not reported); number analyzed is 10 per group | | | | | | General comments: See below Quality assessment: Overall rating: Fair Comments:; - Small study; - Single center; - Number of patients randomized to various treatment groups NR; - See comments immediately below, under Applicability; Applicability:; - Probably does not reflect equivalent doses of enalapril and losartan, biasing results in favor or losartan; - Reports only mean arterial pressure (not SBP, DBP), so difficult to compare to other studies; - Unique dialysis population; may not generalize to non-dialysis hypertensive patients
Shibasaki, Masaki, Nishiue, et al., 2002 #1622
Shibasaki, Masaki, Nishiue, et al., 2002 #1622 | | | | | | | | | | Losartan | Enalapril | Amlodipine
Shibasaki, Masaki, Nishiue, et al., 2002 #1622
Shibasaki, Masaki, Nishiue, et al., 2002 #1622 | | | | | | | Baseline | | | 101.5 (4) | 101.2 (3.3) | 99.3 (2.2)
Shibasaki, Masaki, Nishiue, et al., 2002 #1622
Shibasaki, Masaki, Nishiue, et al., 2002 #1622 | | | | | | | 6 mo | | | 90.8 (2.5) | 90.1 (0.9) | 88.3 (1.7)
Shibasaki, Masaki, Nishiue, et al., 2002 #1622
Shibasaki, Masaki, Nishiue, et al., 2002 #1622 | | | | | | | P < 0.05 for all pre-post differences. No p-values reported for between-group differences. 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: 1 death (treatment group not specified) 4) Morbidity: 1 MI (treatment group not specified) 5) Safety: 7 patients withdrawn from study and not included in analysis:; - 1 had heart attack; - 1 switched from hemo to peritoneal dialysis; - 1 had myocarditis; - 1 had death from pulmonary bleeding; - 3 transferred to other hospitals; No information on initial treatment arm for above withdrawals 6) Specific adverse events: NR except AEs leading to withdrawal (see immediately above) 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: Mean (SD) Left Ventricular Mass Index (g/m^2^)
Shibasaki, Masaki, Nishiue, et al., 2002 #1622
Shibasaki, Masaki, Nishiue, et al., 2002 #1622 | | | | | | | | | | Losartan | Enalapril | Amlodipine
Shibasaki, Masaki, Nishiue, et al., 2002 #1622
Shibasaki, Masaki, Nishiue, et al., 2002 #1622 | | | | | | | Baseline | | | 154.5 (9.9) | 155.6 (14.3) | 156.6 (7.3)
Shibasaki, Masaki, Nishiue, et al., 2002 #1622
Shibasaki, Masaki, Nishiue, et al., 2002 #1622 | | | | | | | 6 mo | | | 114.6 (5.8) | 135.3 (10.4) | 137.2 (4.1)
Shibasaki, Masaki, Nishiue, et al., 2002 #1622
Shibasaki, Masaki, Nishiue, et al., 2002 #1622 | | | | | | | Change | | | -24.7 (3.2) | -11.2 (4.1) | -10.5 (5.2)
Shibasaki, Masaki, Nishiue, et al., 2002 #1622
Shibasaki, Masaki, Nishiue, et al., 2002 #1622 | | | | | | | P < 0.05 for all pre-post for losart and enalapril, but not amlodipine P< 0.05 for difference in losartan group compared to enalapril or amlodipine They also report measurements of interventricular septum, posterior wall, end-diastolic volume index, collapsibility index of IVC and LV ejection fraction 12) Creatinine/GFR: Mean (SD) serum Cr (mg/mL):
Shibasaki, Masaki, Nishiue, et al., 2002 #1622
Shibasaki, Masaki, Nishiue, et al., 2002 #1622 | | | | | | | | | | Losartan | Enalapril | Amlodipine
Shibasaki, Masaki, Nishiue, et al., 2002 #1622
Shibasaki, Masaki, Nishiue, et al., 2002 #1622 | | | | | | | Baseline | | | 9.0 (0.4) | 9.9 (0.7) | 8.7 (0.5)
Shibasaki, Masaki, Nishiue, et al., 2002 #1622
Shibasaki, Masaki, Nishiue, et al., 2002 #1622 | | | | | | | 6 mo | | | 9.2 (0.5) | 10.2 (0.5) | 9.4 (0.9)
Shibasaki, Masaki, Nishiue, et al., 2002 #1622
Shibasaki, Masaki, Nishiue, et al., 2002 #1622 | | | | | | | 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Simons, Ortiz, and Calcino, 2008 #132 | Geographical location: Australia Study dates: Jan 2004 – Dec 2006 Funding source: Project was commissioned by Solvay Pharmaceuticals Australia Interventions: Analysis of patients prescribed antihypertensive medications, mostly (86%) by general practitioners. Analysis restricted to patients using ARBs, ACEIs, or calcium-channel blockers, including products combined with a diuretic. Were additional anti-hypertension medications allowed: Yes If Yes to above, was this done: At discretion of clinician/investigator Study design: Other – retrospective analysis of 10% random sample for AHT drugs Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: NA; Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: 2-year period of data collection Duration of post-treatment followup: NA | Number of patients: N = 48,690; - Screened for inclusion: NR; - Eligible for inclusion: 48,690; - Randomized: NA; - Began treatment: NA; - Completed treatment: NA; - Withdrawals/losses to followup: NA; Age: Range: < 50: 6330 (13%) 50-69: 18,502 (38%) ≥ 70: 23,858 (49%) Sex (n [%]): Female: 27,266 (56%) Male: 21,424 (44%) Race/ethnicity (n [%]): NR Baseline blood pressure: NR Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: All Australian long-term health concession card holders, for whom all prescriptions are recorded. Analysis restricted to patients using ARBs, ACEIs, or calcium-channel blockers, including products combined with a diuretic. Inclusion criteria: Analysis was performed on a cohort of patients who had been prescribed one of the eligible drugs during the period 1/2004 to 9/2006, but for whom no prescription for any antihypertensive medication had been filled during the previous 6 months. Exclusion criteria: See above. | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: [underlined: Cessation] defined as no prescription refills for at least 3 calendar months. [underlined: Persistence] defined as remaining on therapy (i.e., no cessation). “No major differences in persistence patterns between patients taking A2RAs [ARBs] and ACEIs.” “Within the A2RA [ARB] class, patients commencing on candesartan or telmisartan showed the best apparent persistence (by a margin of 10%-20%); within the ACEI class, patients prescribed perindopril showed the best apparent persistence (about 25% better than other class members).” A medication possession ratio (MPR) was calculated for patients persisting with treatment as a surrogate for [underlined: adherence]. “Median MPRs were close to 100%, with the notable exception of captopril (72%).” Detailed data provided in Tables 1-4 of article. 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | | General comments: Assessed only persistence and a surrogate for adherence Quality assessment: Overall rating: Fair Comments: Aggregate data and retrospective study, but sample is probably representative of study population Applicability: Limited to a subset of Australian Medicare patients

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Solomon, Appelbaum, Manning, et al., 2009 #69 ALLAY (Aliskiren in Left-Ventricaular Hypertrophy) study | Geographical location: 77 centers in 8 countries (specific locations NR) Study dates: NR Funding source: Novartis Pharmaceuticals Corp., East Hanover, NJ “The study was designed jointly by the academic steering committee and the sponsor. The sponsor was involved in the study management, data collection, and data analysis.” Interventions:; 1. Aliskiren 150 mg/d, increased to 300 mg/d after 2 weeks (n = 154); 2. Losartan 50 mg/d, increased to 100 mg/d after 2 weeks (n = 152); 3. Aliskiren plus losartan, same dosage and titration as above (n = 154); Were additional anti-hypertension medications allowed: Yes If Yes to above, was this done: Per protocol. Could add diuretics during first week. Additional non-RAAS inhibitor or non-beta-blockers could be added during course of the study to reach BP goal < 140/90 for nondiabetics or < 130/80 for diabetics. Study design: RCT, parallel-group. Randomization stratified according to ACEI/ARB use or not prior to study. Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: Yes; Double-dummy design. Was allocation concealment adequate?: Yes Baseline/run-in period: 2 weeks for patients not on an ACEI or ARB at time of enrollment; 3 months for patients on an ACEI or ARB, during which time they discontinued the ACEI or ARB (non-RAAS blocking agents could be prescribed to control BP during this period) Duration of treatment: 2 weeks of titration, plus 34 weeks of maintenance Duration of post-treatment followup: None (last assessment 34 weeks after start of treatment) | Number of patients: N = 460; - Screened for inclusion: 1104; - Eligible for inclusion: 465; - Randomized: 465; - Began treatment: 465; - Completed treatment: 400/465 (86%); - Withdrawals/losses to followup: 65/465 (14%); Of the 465 randomized, 5 were excluded from analysis because of data quality concerns. Age: Mean (SD): 58.8 ±10.4 Sex (n [%]): Female: 112 (24.3%) Male: 348 (75.7%) Race/ethnicity (n [%]): White: 433 (94.1%) Other: 27 (5.9%) Baseline blood pressure: Assessed at each visit with a calibrated standard sphygmomanometer. Mean of 3 measurements while sitting. [underlined: Aliskiren:] SBP, mm Hg (SD): 145.7 (14.1) DBP, mm Hg (SD): 89.2 (9.6) [underlined: Losartan:] SBP, mm Hg (SD): 146.1 (13.4) DBP, mm Hg (SD): 89.0 (10.0) Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): | | | | | 1) Blood pressure: Only patients who were treated for at least 28 weeks and had both CMR measures were included in the efficacy population (aliskiren n = 133; losartan n = 129; combo n = 138; these n's refer to outcomes #2 & 11 below; full sample used for #1, 5, 6) BP reduction, mm Hg (SD): Aliskiren: SBP: 6.5 (14.9) DBP: 3.8 (10.1) Losartan: SBP: 5.5 (15.6) DBP: 3.7 (10.7) Figure 3 in paper reports BP changes at multiple time points. 2) Rate of use of a single antihypertensive agent for BP control: Aliskiren: 45/133 (34%) Losartan: 45/129 (35%) See Table 5 in paper for further details. 3) Mortality: No deaths 4) Morbidity: NR 5) Safety: Any AE (n [%]): Aliskiren: 91/154 (59%) Losartan: 82/152 (54%) Serious AEs (n [%]): Aliskiren: 10/154 (6.5%) Losartan: 13/152 (9%) Discontinuations due to AEs (n [%]): Aliskiren: 4/154 (3%) Losartan: 10/152 (7%) 6) Specific adverse events: Most common AEs (> 5%): | | | | | | General comments: Results of combination treatment not included in this table Quality assessment: Overall rating: Good Comments: Unclear why some assessments (like those for outcome 2, at left) were reported in subcohort that underwent cMRI Applicability: Good applicability for head-to-head comparison of aliskiren and losartan
Solomon, Appelbaum, Manning, et al., 2009 #69 ALLAY (Aliskiren in Left-Ventricaular Hypertrophy) study | | | | | Aliskiren | Losartan | | | [underlined: Aliskiren] | | [underlined: Losartan]
Solomon, Appelbaum, Manning, et al., 2009 #69 ALLAY (Aliskiren in Left-Ventricaular Hypertrophy) study | | | | | | | Headache | | 14 (9%) | | 8 (5%)
Solomon, Appelbaum, Manning, et al., 2009 #69 ALLAY (Aliskiren in Left-Ventricaular Hypertrophy) study | | History of diabetes | | | 35(22.7) | 34(22.4) | Nasopharyngitis | | 11 (7%) | | 13 (9%)
Solomon, Appelbaum, Manning, et al., 2009 #69 ALLAY (Aliskiren in Left-Ventricaular Hypertrophy) study | | Current smoker | | | 33(21.4) | 29(19.1) | Diarrhea | | 6 (4%) | | 9 (6%)
Solomon, Appelbaum, Manning, et al., 2009 #69 ALLAY (Aliskiren in Left-Ventricaular Hypertrophy) study | | Recruitment setting: NR Inclusion criteria:; - History of or newly diagnosed HTN with SBP/DBP ≥ 140/90 mmHg but < 180/110 mmHg; - Confirmed LV wall thickness in any wall by a screening echocardiogram of ≥ 13 mm; - BMI > 25 kg/m^2^; Exclusion criteria:; - LVEF < 40%; - Required continued treatment with an ACEI or ARB; - Patients treated at entry with an ACEI or ARB who did not complete the 3-month washout period; - Severe BP elevation; - Serum creatinine > 1.7 mg/dL at visit 1; - Severe obesity (BMI ≥ 42 kg/m^2^); - Patients with pacemakers, implantable cardioverter-defibrillators, or defibrillators; - History of MI, coronary artery bypass surgery, percutaneous coronary intervention, transient ischemic attack, or stroke within 6 months of study entry\. | | | | | No statistically significant differences between groups. 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: LV mass assessed via cardiovascular magnetic resonance (CMR), pre-post intervention. “Highly significant reductions in LVMI from baseline in all treatment groups.” See Table 3 and Figure 4 in paper for details. 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Sonoda, Aoyagi, Takenaka, et al., 2008 #120 | Geographical location: Japan Study dates: NR Funding source: NR Interventions: Nonrandomized allocation to:; - Losartan 50 mg/d (n = 22);; - Enapril or imidapril 5 mg/d (n = 14; of these, 11 received enalapril and 3 received imidapril);; 0 Control (no ACEI or ARB; n = 14) Were additional anti-hypertension medications allowed: Yes If Yes to above, was this done: NR Study design: Nonrandomized, 3-arm, parallel-group Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: NR; Was allocation concealment adequate?: NA Baseline/run-in period: NR Duration of treatment: 12 months Duration of post-treatment followup: None (last assessment after 12 months of treatment) | Number of patients: N = 50; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: NA; - Began treatment: 50; - Completed treatment: 50; - Withdrawals/losses to followup: 0 (“none of the patients dropped out of the study”); Age: Mean (SD): 64.1 ± 9.3 Sex (n [%]): NR Race/ethnicity (n [%]): NR Baseline blood pressure: Assessment method for BP not reported [underlined: Losartan], mm Hg (SD): SBP: 138 (25) DBP: 82 (12) Mean: 101 (14) [underlined: Enalapril or Imidapil], mm Hg (SD): SBP: 127 (26) DBP: 67 (11) Mean: 92 (11) Concurrent non-hypertension medications (n [%]): | | | | | 1) Blood pressure: [underlined: Losartan], mm Hg (SD): SBP: 127 (19) DBP: 75 (10) Mean: 92 (11) [underlined: Enalapril or imidapil], mm Hg (SD): SBP: 125 (24) DBP: 71 (14)) Mean: 89 (16) 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: Cholesterol, mg/dL (SD): [underlined: Losartan] Baseline: 202.1 (23.5) Followup: 188.8 (24.1) [underlined: Enalapril or Imidapil] Baseline: 192.7 (21.7) Followup: 200.2 (19.2) Triglycerides, mg/dL (SD): [underlined: Losartan] Baseline: 199.5 (137.0) Followup: 205.0 (126.0) [underlined: Enalapril or imidapil] Baseline: 106.0 (58.5) Followup: 156.0 (128.0) Followup results were not statistically significant between groups 9) Progression to type 2 diabetes: Prevalence of “diabetes mellitus” at baseline and 12-mo followup: [underlined: Losartan] Baseline: 5/22 (23%) Fu: 5/22 (23%) [underlined: Enalapril or Imidapril] Baseline: 1/14 (7%) Followup: 1/14 (7%) Prevalence of “uncontrollable diabetes mellitus” at baseline and 12-mo followup: [underlined: Losartan] Baseline:2/22 (9%) Followup: 3/22 (14%) [underlined: Enalapril or Imidapril] Baseline: 1/14 (7%) Followup: 1/14 (7%) 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR 14) Other: Intima-media thickness change from baseline: Losartan: -0.076 ± 0.118; Enalapril or imidapril: -0.073 ± 0.109 No difference between those 2 arms, but significant decline compared to baseline in both arms | | | | | | General comments: Significant potential bias due to poor study design and inadequate reporting Quality assessment: Overall rating: Poor Comments:; - Non randomized; - Open-label; - Small sample size; - 2 different ACEIs in ACEI arm; - Many baseline differences between study arms; - Inadequate reporting of patient population, methods, and results (no BP results); Applicability: Inadequate reporting of study populations, methods, interventions, and results
Sonoda, Aoyagi, Takenaka, et al., 2008 #120 | | | | | [underlined: Losartan] | [underlined: Enal/imidapril]
Sonoda, Aoyagi, Takenaka, et al., 2008 #120 | | Aspirin | | | 9/22 (41%) | 7/14 (50%)
Sonoda, Aoyagi, Takenaka, et al., 2008 #120 | | Statins | | | 6/22 (27%) | 3/14 (21%)
Sonoda, Aoyagi, Takenaka, et al., 2008 #120 | | β-blocker | | | 6/22 (27%) | 3/14 (21%)
Sonoda, Aoyagi, Takenaka, et al., 2008 #120 | | Comorbidities (n [%]):
Sonoda, Aoyagi, Takenaka, et al., 2008 #120 | | | | | [underlined: Losartan] | [underlined: Enal/imidapril]
Sonoda, Aoyagi, Takenaka, et al., 2008 #120 | | Diabetes | | | 5/22 (23%) | 1/14 (7%)
Sonoda, Aoyagi, Takenaka, et al., 2008 #120 | | Uncontrolled diabetes | | | 3/22 (14%) | 1/14 (7%)
Sonoda, Aoyagi, Takenaka, et al., 2008 #120 | | Recruitment setting: NR Inclusion criteria: Systemic HTN Exclusion criteria: Patients on hemodialysis or with renal failure

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Souza-Barbosa, Ferreira-Melo, Ubaid-Girioli, et al., 2006 #234 | Geographical location: Campinas, SP, Brazil Study dates: NR Funding source: Fundação de Amparo à Pesquisa do Estado de São Paulo Interventions: Five groups:; 1. Normotensive controls (n = 25);; 2. HCTZ 25-50 mg/d (n = 18);; 3. Quinapril 20 mg/d (n = 16);; 4. Irbesartan 150 mg/d (n = 14);; 5. Quinapril 20 mg/d plus irbesartan 150 mg/d (n = 25); Controls administered neither drugs nor placebo Were additional anti-hypertension medications allowed: NR Study design: RCT, parallel-group. 5 arms total: 1 arm comprised of normal controls, 4 arms comprised of patients with hypertension randomized to a drug regimen Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: Yes; Was allocation concealment adequate?: NR Baseline/run-in period: None Duration of treatment: 12 weeks Duration of post-treatment followup: None (last measurement 12 weeks after start of treatment). | Number of patients: N = 88 (25 normotensives and 63 hypertensives); - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: NR; - Began treatment: NR; - Completed treatment: NR; - Withdrawals/losses to followup: NR; Note: sample sizes were provided for each intervention group, but it is not clear whether those sample sizes were for patients who started treatment, completed the 12-month study, or both Age: Mean (SD): 49 ±7.6 Sex (n [%]): Female: 51 (58.0%) Male: 37 (42.0%) Race/ethnicity (n [%]): Black: 49 (55.7%) Other: (44.3%) Baseline blood pressure: Mean 24-hour SBP, using ambulatory blood pressure monitoring (Spacelabs). [underlined: Quinapril] SBP, ABPM, mm Hg (SD): 150 (14) DBP, ABPM, mm Hg (SD): 94 (11) [underlined: Irbesartan] SBP, ABPM, mm Hg (SD): 168 (15) DBP, ABPM, mm Hg (SD): 90 (12) Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: Hypertensive subjects recruited from patients diagnosed in the outpatient hypertension clinic at a university hospital Inclusion criteria: Diagnosis of hypertension in outpatient hypertension clinic Exclusion criteria:; - Secondary forms of HTN; - Pheochromocytoma; - Renal artery stenosis; - Primary hyperaldosteronism; - Aortic coarctation; - Impaired renal function; - Ischemic heart disease, liver diseases, and other major disease; - Recent use of medicines that affected vascular function, including statins, prostaglandin inhibitors, vitamins, contraceptives (within the previous 2 months), and acetylsalicylic acid (within the previous 7 days); - Dyslipidemia, DM, or evidence of hepatic, renal, or hematologic dysfunction | | | | | 1) Blood pressure: [underlined: Quinapril] SBP, ABPM, mm Hg (SD): 117 (16) DBP, ABPM, mm Hg (SD): 76 (10) [underlined: Irbesartan] SBP, ABPM, mm Hg (SD): 136 (8) DBP, ABPM, mm Hg (SD): 71 (10) 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | | General comments:; - Results for other 3 study arms not included here; - Study also includes data on flow-mediated dilation to assess endothelial function; Quality assessment: Overall rating: Poor Comments: Inadequate reporting of methods, recruitment, treatment, and followup Applicability:; - Baseline differences in BP between groups; - Inadequate reporting of methods, recruitment, treatment, followup; - No information about cointerventions

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Spinar, Vitovec, Soucek, et al., 2009 #36 | Geographical location: Czech Republic Study dates: Jan 06 – Dec 07 Funding source: The Ministry of Education of the Czech Republic (0021 622 402) Interventions: Group A (CORD 1A): 4016 patients previously on an ACEI for > 3 months were switched to losartan 50 mg/day. Dose could be lowered to 25 mg at clinician's discretion. If BP ≥ 140/90 at 1 or more months, dose increased to 100 mg. If BP ≥ 140/90 after ≥ 3 months of treatment, another hypertensive drug added (usually a thiazide diuretic). Group B (CORD 1B): 3813 patients with stable BP ≥ 140/90 for at least 3 months prior, and not currently treated with an ACEI or ARB. Ramipril (recommended 5 mg, but could be 2.5 mg) vs. losartan (recommended 50 mg, but could be 25 mg). Dose increased at ≥ 1 month if BP ≥ 140/90. If BP ≥ 140/90 after ≥ 3 months of treatment of ramipril 10 mg or losartan 100 mg, another hypertensive drug added (usually a thiazide diuretic). Were additional anti-hypertension medications allowed: Yes, both prior to enrollment, and as additional treatment during study period If Yes to above, was this done: At discretion of clinician/investigator, within parameters specified per protocol Study design: CORD 1A: Prospective cohort, with pre-intervention comparison C0RD 1B: RCT, parallel-group Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: NR; Was allocation concealment adequate?: No Baseline/run-in period: NA Duration of treatment: 12 months Duration of post-treatment followup: None. Followup upon completion of 12-month treatment period | Number of patients: N = 7829 with 6-month followup data, but no clear reporting of the number of patients enrolled [underlined: CORD 1A:]; - Screened for inclusion: 11,284; - Eligible for inclusion: NR; - Randomized: NA; - Began treatment: Ambiguous and possibly erroneous reporting. The abstract reported that 4016 patients were enrolled, but this is also the number of patients that completed the 6-month assessment.; - Completed treatment: 4016 at 6 months, and 3022 at 12 months; - Withdrawals/losses to followup: NR. By inference, based on ambiguous data reporting in Figure 1 and Table 1, there were no withdrawals, death, or losses to followup in either CORD 1A or CORD 1B at the 6-month followup, except for 72 patients withdrawn because of adverse events. Which group these 72 patients were originally allocated to is not reported. If 72 is the total number of patients who withdrew or were lost to followup, the retention rate at 6 months for CORD 1A and 1B combined would be 7757/7829 = 99%. The corresponding 12-mo retention rate (assuming 7829 were enrolled) is 5832/7829 = 75%.; [underlined: CORD 1B:]; - Screened for inclusion: 11,284; - Eligible for inclusion: NR; - Randomized: Ambiguous and possibly erroneous reporting. The abstract reported that 3813 patients were enrolled (1926 in ramipril group and 1887 in losartan group), but this is also the number of patients that completed the 6-month assessment.; - Began treatment: See above. It appears that data are reported only for patients who completed the 6-month followup.; - Completed treatment: Ramipril: 1926 at 6 months and 1416 at 12 months. Losartan: 1887 at 6 months and 1394 at 12 months; - Withdrawals/losses to followup: NR relative to start of treatment, but 510/1926 (26%) and 493/1887 (26%) lost to followup or withdrawn between months 6 and 12 for ramipril and losartan, respectively, not counting the 72 patients in CORD 1A and 1B reported to have been withdrawn because of side effects.; Age: CORD 1A: Mean (SD): 62.6 ± 11.6 CORD 1B:; - Ramipril: Mean (SD): 60.4 ± 12.5; - Losartan: Mean (SD): 60.6 ± 11.8; Sex (n [%]): CORD 1A: Female: 53.1% (calculated n = 2132) CORD 1B:; - Ramipril: Female: 49.0% (calculated n = 944); - Losartan: Female: 52.1% (calculated n=983); Race/ethnicity (n [%]): NR Baseline blood pressure: [underlined: CORD 1A] SPB: 147.4 (SD 14.8) mm Hg DBP: 87.7 (SD9.3) mm Hg [underlined: CORD 1B, ramipril] SBP: 155.9 (SD 13.1) DBP: 134.9 (SD 10.5) [underlined: CORD 1B, losartan] SBP: 156.5 (SD 13.1) DBP: 93.4 (SD 8.8) Concurrent non-hypertension medications (n [%]): CORD 1A: Aspirin: 36% Warfarin: 4% Statin: 44% Nitrate: 15% Oral antidiabetic med: 15% CORD 1B: Aspirin: 31% Warfarin: 3% Statin: 38% Nitrate: 12% Oral antidiabetic med: 12% Comorbidities (n [%]): CORD 1A: Diabetes mellitus: 33% Previous MI: 13% Dyslipidemia: 61% CORD 1B: Diabetes mellitus: 29% Previous MI: 12% Dyslipidemia: 55% Recruitment setting: Patients of 585 doctors in the Czech Republic Inclusion criteria:; - Treated with an ACEI for > 3 months; - BP < 160/100 mmHg; - Treatment with additional antihypertensive agents, other than an ARB, was allowed; Exclusion criteria: Any documented cardiovascular event during the 3 months prior to screening | | | | | 1) Blood pressure: Blood pressure at 12 months (SBP/DBP, mmHg, mean [± SD]): CORD 1A: 133.6 ± 10.3 / 79.0 ± 6.5 CORD 1B:; - Ramipril: 134.1 ± 11.2 / 79.3 ± 6.9; - Losartan: 134.5 ± 11.3 / 80.1 ± 6.6; No statistically significant differences between groups Percentage of patients moving from hypertension to normotension at 6 months: CORD 1A: 31.7% CORD 1B:; - Ramipril: 45.6%; - Losartan: 46.6%; 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: CORD 1A: 6 deaths (0.1%) CORD 1B: 4 deaths in ramipril group (0.2%) and 5 deaths in losartan group (0.2%) 4) Morbidity: CORD 1A:; - MI: 7/4016 (0.2%); - Stroke: 14/4016 (0.3%); - New diabetes mellitus: 9/4016 (0.2%) | | | | | | General comments: Unable to assess for potentially significant bias because of inadequate and ambiguous reporting Quality assessment: Overall rating: Poor Comments: Inadequate reporting of study design, methods, and results. It appears that patients who enrolled and/or started treatment but did not complete the 6-month assessment were excluded from all analyses, including baseline analyses. Study design, however, is innovative, with potentially informative findings had they been reported in a way that would have allowed unambiguous interpretation. Applicability:; - Selection and withdrawal of participants poorly reported; - Indirect comparison in CORD 1A
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | CORD 1B: | | [underlined: Ramipril] | | [underlined: Losartan]
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | - MI: | | 4 (0.2%) | | 3 (0.2%)
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | - Stroke | | 8 (0.4%) | | 9 (0.5%)
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | - New diabetes: | | 6 (0.3%) | | 5 (0.3%)
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | 5) Safety: See Morbidity above. 6) Specific adverse events: Incidence of cough, n (%)
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | [underlined: CORD 1A] | | [underlined: Ramipril] | | [underlined: Losartan]
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | 3 (< 0.1%) | | 33 (2%) | | 4 (0.2%)
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | 7) Persistence/adherence: NR 8) Lipid levels: Cholesterol, mmol/L:
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | | | [underlined: Baseline] | | [underlined: Month 12]
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | CORD 1A | | 5.44.4 ± 0.4 | | 5.2 ± 0.8
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | CORD 1B
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | - Ramipril | | 5.4 ± 1.0 | | 5.2 ± 0.8
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | - Losartan | | 5.5 ± 1.0 | | 5.3 ± 0.9
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | Triglycerides, mmol/L:
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | | | [underlined: Baseline] | | [underlined: Month 12]
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | CORD 1A | | 1.9 ± 0.9 | | 1.8 ± 0.8
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | CORD 1B
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | - Ramipril | | 1.9 ± 0.9 | | 1.8 ± 0.7
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | - Losartan | | 1.9 ± 0.9 | | 1.8 ± 0.7
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | Within-group changes from baseline and between-groups comparisons of these changes were not statistically significant 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: Glycemia, mmol/L:
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | | | [underlined: Baseline] | | [underlined: Month 12]
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | CORD 1A | | 5.9 [underlined: +] 1.6 | | 5.7 [underlined: +] 1.4
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | CORD 1B
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | - Ramipril | | 5.9 [underlined: +] 1.8 | | 5.7 [underlined: +] 1.3
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | - Losartan | | 5.8 [underlined: +] 1.6 | | 5.7 [underlined: +] 1.5
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | 11) LV mass/function: NR 12) Creatinine/GFR: Creatinine, micromol/L:
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | | | [underlined: Baseline] | | [underlined: Month 12]
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | CORD 1A | | 91.5 [underlined: +] 20.7 | | 91.6 [underlined: +] 19.5
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | CORD 1B
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | - Ramipril | | 89.5 [underlined: +] 18.5 | | 90.2 [underlined: +] 18.4
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | - Losartan | | 91.1 [underlined: +] 20.1 | | 91.2 [underlined: +] 20.2
Spinar, Vitovec, Soucek, et al., 2009 #36 | | | | | | | 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Spoelstrade Man, van Ittersum, Schram, et al., 2006 #260 | Geographical location: A University Medical Center in Amsterdam & 5 other hospitals in the same region Study dates: July 1998 – Oct 2001 Funding source: AstraZeneca provided funding but had no influence on the data analyses or manuscript preparation Interventions: Patients randomized to:; - HCTZ 12.5 mg (n = 24); - Candesartan 8 mg (n = 24); - Lisinopril 10 mg (n = 22); Titration period of 4-6 months after randomization to achieve target BP of 130/85, or a sitting BP decrease of more than 10% combined with a DBP < 85 Were additional anti-hypertension medications allowed: Yes If Yes to above, was this done: Stepwise titration of dosage and addition of other medications per protocol. HCTZ was co-administered in all groups. Study design: RCT, parallel-group, double blind Randomization occurred after run-in period Blinding:; - Patients: Yes at randomization, but not for stepwise increase in dosage or addition of new drugs.; - Providers: Yes at randomization, but not for stepwise increase in dosage or addition of new drugs.; - Assessors of outcomes: Yes; Double-dummy design, with 2 placebo pills taken per day in addition to active drug. Unblinded protocol for additional therapy as needed. Was allocation concealment adequate?: NR Baseline/run-in period: 1 month Duration of treatment: 12-month treatment period after titration period, beginning with either achievement of target BP, or after completion of 6-month titration period Duration of post-treatment followup: None. Last followup 12 months after beginning of treatment period (which is also the end of the titration period) | Number of patients: N = 70; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 70; - Began treatment:; - Completed treatment:; - Withdrawals/losses to followup: 10 (1 lost to followup; 9 discontinued intervention); Age: Mean (SD): 61.7 (7) Range: 35-70 Sex (n [%]): Female: 27 (38.6%) Male: 43 (61.4%) Race/ethnicity (n [%]): Caucasian: 70 (100%) Baseline blood pressure: Ambulatory blood pressure monitoring with a Spacelabs 90207 monitor Mean 24h SBP, mm Hg (SD): | | | | | 1) Blood pressure: Sitting BP:; - Candesartan: 67% achieved BP goals after the titration phase, with the median use of 3 antihypertensive drugs; - Lisinopril: 68% achieved BP goals after the titration phase, with the median use of 3 antihypertensive drugs | | | | | | General comments:; - Study initially powered to detect a significant change in LVMI, but recruitment ended before enrolling the anticipated 38 patients/group; - Enrolled only patients with DM and HTN; Quality assessment: Overall rating: Good Comments:; - Adequate blinding; - Head-to-head comparison of antihypertensive therapy strategies with either candesartan or lisinopril as initial therapy; Applicability:; - Complicated drug titration protocol; - Little information about patient population; - Extensive exclusion criteria
Spoelstrade Man, van Ittersum, Schram, et al., 2006 #260 | | | | | | | Mean BP at 12 months, mm Hg (SD)
Spoelstrade Man, van Ittersum, Schram, et al., 2006 #260 | | | | | | | | | [underlined: Candesartan] | | [underlined: Lisinopril]
Spoelstrade Man, van Ittersum, Schram, et al., 2006 #260 | | | | | | | SBP:
Spoelstrade Man, van Ittersum, Schram, et al., 2006 #260 | | | | | | | | | 128 (13) | | 126 (15)
Spoelstrade Man, van Ittersum, Schram, et al., 2006 #260 | | | | | | | | | 76 (9) | | 73 (7)
Spoelstrade Man, van Ittersum, Schram, et al., 2006 #260 | | [underlined: Candesartan] | | | [underlined: Lisinopril] | | 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: Complete followup:; - Candesartan: 20/24 (83%); - Lisinopril: 21/22 (95%); 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: LVM decreased by 4% at 6 months and 10% at 12 months in both groups. 12) Creatinine/GFR: NR 13) Proteinuria: NR
Spoelstrade Man, van Ittersum, Schram, et al., 2006 #260 | | 136 (12) | | | 136 (13)
Spoelstrade Man, van Ittersum, Schram, et al., 2006 #260 | | Mean 24h DBP, mm Hg (SD):
Spoelstrade Man, van Ittersum, Schram, et al., 2006 #260 | | [underlined: Candesartan] | | | [underlined: Lisinopril]
Spoelstrade Man, van Ittersum, Schram, et al., 2006 #260 | | 79 (8) | | | 81 (9)
Spoelstrade Man, van Ittersum, Schram, et al., 2006 #260 | | Office SBP, mm Hg (SD):
Spoelstrade Man, van Ittersum, Schram, et al., 2006 #260 | | [underlined: Candesartan] | | | [underlined: Lisinopril]
Spoelstrade Man, van Ittersum, Schram, et al., 2006 #260 | | 151 (14) | | | 149 (9)
Spoelstrade Man, van Ittersum, Schram, et al., 2006 #260 | | Office DBP, mm Hg (SD):
Spoelstrade Man, van Ittersum, Schram, et al., 2006 #260 | | [underlined: Candesartan] | | | [underlined: Lisinopril]
Spoelstrade Man, van Ittersum, Schram, et al., 2006 #260 | | 94 (10) | | | 93 (7)
Spoelstrade Man, van Ittersum, Schram, et al., 2006 #260 | | Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: Outpatient clinic in a medical center and 5 other hospitals Inclusion criteria:; - Type 2 DM for ≥ 6 months; - Age 35-70; - Caucasian ethnicity; - Urinary albumin excretion < 100 mg/24 hours; Exclusion criteria:; - Pregnant or planning pregnancy; - History of MI, angina pectoris, coronary artery bypass surgery, angioplasty, stroke, congestive heart failure, malignancy or other serious illnesses; - Serum creatinine > 140 μmol; - Use of antihypertensive medication in the previous month or ACEIs in the previous 3 months; - BMI > 35 kg/m^2^; - Alcohol and/or drug abuse; - Participation in other clinical trials

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Tedesco, Natale, and Calabro, 2006 #249 | Geographical location: Naples, Italy Study dates: NR Funding source: NR Interventions:; - Carvedilol 25 mg; - Amlodipine 10 mg; - Enalapril 20 mg; - Losartan 50 mg; After 2 months, nonresponders received a low-dose thiazide diuretic, and after 4 months either amlodipine (enalapril, carvedilol, losartan groups) or carvedilol (amlodine group) Discontinuation of treatment and withdrawal from study occurred when SBP did not decrease by 5 or more mm Hg or when the medication was “not tolerated” Were additional anti-hypertension medications allowed: Yes If Yes to above, was this done: Per protocol (see above) Study design: RCT, parallel-group Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: Previously treated patients who did not have BP controlled by current medication suspended therapy for at least 1 week (by inference, prior to randomization) Duration of treatment: 24 months Duration of post-treatment followup: 0 (24-month visit = final visit) | Number of patients: N = 560; - Screened for inclusion: 560; - Eligible for inclusion: 520 (40 excluded due to white coat HTN); - Randomized: 520; - Began treatment: NR; - Completed treatment: 466; - Withdrawals/losses to followup: Total: 54 (10%); - Withdrawn 2ary to AE's: 25 (5%); - No BP control: 15 (3%); - Lost to followup: 14 (3%); Age: Mean (SD): 54 (10.5) Range: 29-90 Age reported only for the 466 patients who completed the study Sex (n [%]): Female: 186/466 (40.0%) Male: 280/466 (60.0%) Sex distribution reported only for the 466 patients who completed the study Race/ethnicity (n [%]): Caucasian: 560 (100%) Baseline blood pressure: By mercury sphygmomanometer on nondominant arm in the early morning, sitting, by a trained investigator, at clinic visits. Mean of 3 readings 10 minutes apart, recorded to the nearest 2 mm. Spacelabs model 90207 monitor used for ABPM. | | | | | 1) Blood pressure: Response to treatment defined as mean sitting BP < 140/90 or a decrease of 10/10 mm Hg in BP from baseline No significant differences in outcomes between study arms | | | | | | General comments: Appropriate study design with moderate quality reporting, appropriate control groups, and relatively large sample size Quality assessment: Overall rating: Good Comments: Reasonably high-quality study, given the limitations of an unblinded clinical trial with moderately good reporting of methods and results Applicability:; - Generalizability difficult to determine because of insufficient information about the recruitment setting and patient characteristics; - Relatively restrictive exclusion criteria; - Limited reporting on cointerventions over the course of the 24 months; - All Caucasian sample
Tedesco, Natale, and Calabro, 2006 #249 | | | | | | | BP, 24 months (mm Hg): | | [underlined: Enalapril] | | [underlined: Losartan]
Tedesco, Natale, and Calabro, 2006 #249 | | | | | | | Mean 24h SBP: | | 132 ± 8 | | 132 ± 8
Tedesco, Natale, and Calabro, 2006 #249 | | | | | | | Change in SBP: | | -22 | | -23
Tedesco, Natale, and Calabro, 2006 #249 | | | | | | | Mean 24h DBP: | | 85 ± 5 | | 85 ± 5
Tedesco, Natale, and Calabro, 2006 #249 | | | | | | | Change in DBP: | | -13 | | -13
Tedesco, Natale, and Calabro, 2006 #249 | | | | | | | Responders (%): | | [underlined: Enalapril] | | [underlined: Losartan]
Tedesco, Natale, and Calabro, 2006 #249 | | | | | | | One drug: | | 25 | | 23
Tedesco, Natale, and Calabro, 2006 #249 | | | | | | | Two drugs: | | 49 | | 50
Tedesco, Natale, and Calabro, 2006 #249 | | | | | | | Three drugs: | | 26 | | 27
Tedesco, Natale, and Calabro, 2006 #249 | | | | | | | 24h BP< 130/80 | | 71 | | 72
Tedesco, Natale, and Calabro, 2006 #249 | | | | | | | 2) Rate of use of a single antihypertensive agent for BP control: 103/466 (22%) were responders on monotherapy 3) Mortality: NR 4) Morbidity: NR 5) Safety:
Tedesco, Natale, and Calabro, 2006 #249 | | | | | | | Withdrawals due to AEs, n (%) | | [underlined: Enalapril] | | [underlined: Losartan]
Tedesco, Natale, and Calabro, 2006 #249 | | | | | | | | | 5 (4%) | | 2 (2%)
Tedesco, Natale, and Calabro, 2006 #249 | | | | | | | Not statistically significant 6) Specific adverse events:
Tedesco, Natale, and Calabro, 2006 #249 | | | | | | | | | [underlined: Enalapril] | | [underlined: Losartan]
Tedesco, Natale, and Calabro, 2006 #249 | | | | | [underlined: Enalapril] | [underlined: Losartan] | Cough: | | 4 | | 0
Tedesco, Natale, and Calabro, 2006 #249 | | Mean 24h SBP: | | | 154 ± 7 | 155 ± 8 | Dizziness | | 1 | | 2
Tedesco, Natale, and Calabro, 2006 #249 | | Mean 24h DBP: | | | 98 ± 6 | 98 ± 8 | 7) Persistence/adherence: “Medication compliance was adequate, with more than 90% of pills having been taken in each treatment group.” 8) Lipid levels: Significant reduction in total cholesterol (-10 mg/dL; p < 0.03) in the losartan group, and insignificant increase (1 mg/dL) in the enalapril group 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: No significant differences between groups in systolic and diastolic function indexes, LVMI, or diastolic peak velocity ratios (detailed data in Table 3 of paper includes LVMI, LVH, echo parameters) 12) Creatinine/GFR: NR 13) Proteinuria: NR
Tedesco, Natale, and Calabro, 2006 #249 | | Concurrent non-hypertension medications (n [%]): NR. “No patient received concomitant medications known to affect BP or interfere with the metabolic parameters.” Comorbidities (n [%]): NR Recruitment setting: Referral from investigators' outpatient clinic Inclusion criteria: Conventional cuff BP readings used for screening of uncomplicated HTN (SBP 155-169 mmHg and DBP 95-109 mmHg) 24-hr ambulatory BP monitoring (ABPM) used to confirm eligibility (average ABPM BP of ≥ 130/80 mm Hg) Exclusion criteria:; - “White coat HTN”; - Secondary HTN; - Renal failure; - Diabetes mellitus; - Congestive heart failure; - Atrial fibrillation; - Severe valvular heart disease; - Pregnancy or lactation; - Severe obesity; - Ambiguous reporting of whether history of MI or stroke were exclusion criteria

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | Geographical location: 32 centers in Finland, Denmark, Iceland, and Norway Study dates: NR Funding source: NR Interventions:; - Losartan 50 mg (n = 202); - Enalapril 20 mg (n = 205); No dose titration or co-interventions Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: Yes; Was allocation concealment adequate?: NR Baseline/run-in period: 2-wk placebo run-in Duration of treatment: 12 wk Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 407; - Began treatment: 399; - Completed treatment: 382; - Withdrawals/losses to followup: 25; Age: Cannot determine mean age; distribution for total sample: | | | | | 1) Blood pressure: N = 399 total for “all patients treated” analysis Mean (SD) seated trough SBP: | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments:; - No description of recruiting strategy, allocation, or number of screened patients; Applicability:; - Racially homogeneous population (100% white) with very few comorbidities – does not represent general hypertension population; - There were many protocol deviations in the timing of trough BP measurement resulting in a separate analysis (that was likely post-hoc)
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | | | Losartan (n = 200) | | Enalapril (n = 199)
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | Baseline | | 157.5 (17.1) | | 158.8 (16.5)
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | 12 wk | | 146.9 (18.3) | | 146.0 (16.9)
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | Change | | -10.6 (13) | | -12.9 (12.9)
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | p < 0.01 for within-group pre-/post- changes p < 0.05 enalapril vs. losartan Mean (SD) seated trough DBP:
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | Age | | | N | %
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | | | Losartan (n = 200) | | Enalapril (n = 199)
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | < 35 | | | 19 | 4.7
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | Baseline | | 103.1 (6.0) | | 103.7 (6.1)
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | 35-44 | | | 70 | 17.2
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | 12 wk | | 94.7 (9.0) | | 93.0 (7.9)
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | 45-54 | | | 152 | 37.3
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | Change | | -8.4 (7.1) | | -10.6 (7.2)
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | 55-64 | | | 110 | 27.0
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | p < 0.01 for within-group pre-/post- changes p < 0.05 enalapril vs. losartan Also reported is a separate “per protocol” analysis that excluded patients who did not have BP measured at the appropriate trough time Also reported is the distribution of treatment response (defined as “excellent, good, fair, or poor”). These results also favored enalapril (p < 0.05). 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety:
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | > 64 | | | 56 | 13.8
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | | | | Losart, n (%) | Enal, n (%) | p- value
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | Sex (n [%]): Female: 151 (37.1%) Male: 256 (62.9%) Race/ethnicity (n [%]): 100% white Baseline blood pressure: Trough seated BP measured using a standard mercury sphygmomano-meter after 10 min supine rest; average of 3 readings taken at 1-min intervals
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | [underlined: Losartan] | [underlined: Enalapril] | Total AEs | | | 65 (32.2%) | 93 (45.4%) | < 0.01
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | SBP | | | 157.5 ±17.1 | 158.8 ± 16.5
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | DBP | | | 103.1 ± 6.0 | 103.7 ± 6.1 | Possibly drug-related AEs | | | 23 (11.4%) | 52 (25.4%) | < 0.01
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | Concurrent medications (n [%]): Patients discontinued other antihypertensive meds Comorbidities (n [%]): Not listed, but include category of “secondary diagnoses” (not defined) Secondary Diagnoses – “Yes”: Losartan: n = 123 (60.9%) Enalapril: n = 126 (61.5%) Total: n = 249 (61.2%) Recruitment setting: Outpatient primary care clinics Inclusion criteria:; - Age 20-75; - Sitting DBP 95-120 after 2 wk of placebo; Exclusion criteria:; - Previous therapy of > 2 antihypertensive meds; - Secondary hypertension; - Renal impairment (Cr >150 μmol/L); - Proteinuria > 1+ on dipstick; - CVA, TIA, or HTN encephalopathy in last 1 yr; - MI or angina pectoris in last 6 months; - Pregnant or nursing women; - Women of child bearing potential; - Current use of NSAIDs or corticosteroids or drugs known to affect BP; - Uncontrolled DM (fasting BS > 11 mmol/L); - Obesity (arm circumference >41); - Serum potassium < 3.5 or > 5.5; - Abnormal liver function test (twice upper limit of normal); - Hgb level < 100g/dL; - “Other clinically important disease that might interfere with participation”; - Previous adverse reaction or lack of treatment response to ACEI
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | Withdrawals due to AEs | | | 6 (3%) | 14 (6.8%) | NS
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | Withdrawals due to drug-related AEs | | | 3 (1.5%) | 12 (5.9%) | < 0.05
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | 6) Specific adverse events: Headache, edema, rash/itching mentioned as AEs, but not quantified.
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | | | | Losart | Enal | p-value
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | Dry cough at 12 wk | | | 1% | 12.2% | < 0.01
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | 7) Persistence/adherence: NR 8) Lipid levels:
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | | | Losartan (mean change %) | | Enalapril (mean change %)
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | Cholesterol level | | 1.8 | | -0.2
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | HDL cholesterol | | 2.1 | | 1.5
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | Triglycerides | | -3.0 | | 2.3
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control:
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | | | Losartan (mean change %) | | Enalapril (mean change %)
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | Glucose level | | -0.8 | | 0
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | 11) LV mass/function: NR 12) Creatinine/GFR:
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | | | Losartan (mean change %) | | Enalapril (mean change %)
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | Creatinine level | | -0.1 | | 1.7
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | 13) Proteinuria: Reported for subgroup of patients only (n = 93 Danish and Finnish patients) Urinary albumin/creatinine ratio (geometric mean ×/- antilog SD) in total subgroup:
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | | | Losartan (n = 46) | | Enalapril (n = 47)
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | Baseline | | 1.14 ×/-2.48 | | 0.95 ×/-2.45
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | 12 wks | | 0.81 ×/-2.45 | | 0.73 ×/-2.0
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | Differences are significant pre-/post- (p < 0.05), but not between treatments. Urinary albumin/creatinine ratio (geometric mean ×/- antilog SD) in microalbuminuric patients (n = 23):
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | | | Losartan (n = 12) | | Enalapril (n = 11)
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | Baseline | | 4.16 ×/- 1.73 | | 3.62 ×/- 1.69
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | 12 wks | | 1.77 ×/- 3.94 | | 1.52 ×/- 2.21
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606
Tikkanen, Omvik, and Jensen, 1995 #1623 and Nielsen, Dollerup, Nielsen, et al., 1997 #1606 | | | | | | | Differences are significant pre-/posts (p < 0.05), but not between treatments.

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Townsend, Haggert, Liss, et al., 1995 #1624 | Geographical location: Philadelphia, PA (31 centers) Study dates: NR Funding source: NR (one author from Merck) Interventions:; - Losartan: 50 mg once daily switched after 8 weeks, if necessary, to 50 mg losartan plus 12.5 mg HCTZ (n = 132); - Enalapril: 5 mg once daily switched after 4 weeks, if necessary, to 10 mg enalapril and then to 10 mg enalapril and plus 25 mg HCTZ after 8 weeks (n = 136); Titration at each step was required if the SDP remained ≥ 90 mm. Early entry was possible if mean SDBP of 110-115 was evident at baseline and confirmed and confirmed at a repeat visit within 3 days Patients stratified by SDBP. Mild hypertension = mean SDBP 95-104 Moderate =105-115 mm Study medication: Once a day between 6.30-9.30am. On the morning of clinic visits no medication until bp was measured: all measurements at end of 24-hr dosing interval Study design: RCT, parallel-group Blinding:; - Patients: Yes; - Providers: NR; - Assessors of outcomes: Yes; Each patient got an active and a placebo of the alternative treatment using a double blind double dummy design Was allocation concealment adequate?: NR Baseline/run-in period: 4 week placebo run-in (2 placebo tablets each day in the morning, 1 matching losartan and 1 matching enalapril) Duration of treatment: 12 weeks Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion:; - Eligible for inclusion:; - Randomized: 268; - Began treatment: NR; - Completed treatment: NR; - Withdrawals/losses to followup: 31, 21 due to AEs, 10 due to protocol violations; Age: Mean (SD): 54.5, 79.5% < 65 yr Median: NR Range: NR Sex (n [%]): Female: 136 (51%) Male: 132 (49%) Race/ethnicity (n [%]): Black: 65 (25%) White: 148 (63%) Hispanic: 26 (10%) Oriental: 5 (2%) Native American: 1 (0.5%) Other: 3 (0.5%) Baseline blood pressure: At each visit sitting SBP at trough at end of dosing interval and before administration of daily dose. BP measurements after 5 min of rest, in sitting position using a standard mercury sphygmomanometer. Readings repeated to obtain 3 consecutive readings within 1 min interval that did not vary by more than 5 mm from the calculated average of last 3 readings. Primary endpoint was change in mean sitting DBP from baseline to end of study Baseline SiDBP: Losartan: 101 ± 5 Enalapril: 100 ± 4 Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria: Mean SDBP ≥ 95 and ≤ 115 mm, and did not vary by more than 7 mm between measurements Exclusion criteria:; - Previously recd. ACE or ARBs; - Sensitivity or intolerance to either drug; - History of angioedema, heart failure, sec hypertension, malignant hypertension, hypertensive encephalopathy, hypertensive retinopathy, potentially life-threatening arrythmias, decompensated valvular disease, MI, angioplasty, recent coronary bypass surgery, cerebrovascular accident; - Pregnant or breast-feeding women | | | | | 1) Blood pressure: At 12 wk, patients in the losartan group had a mean SBP reduction of 10.3 mm Hg vs. 9.8 mm Hg for enalapril (p = 0.31). 68% of patients taking losartan and 60% of patients taking enalapril reached goal BP (sitting DBP < 90 mm Hg or reduction ≥ 10 mm Hg in sitting DBP vs. baseline; p = 0.16). No other quantitative data reported for overall group results. Subgroup results: | | | | | | General comments:; - Study setting not described (“centers”); Quality assessment: Overall rating: Fair Comments:; - No quantitative data reported for overall group results; Applicability:; - Sites not described
Townsend, Haggert, Liss, et al., 1995 #1624
Townsend, Haggert, Liss, et al., 1995 #1624 | | | | | | | | | | Losart | Enal | p
Townsend, Haggert, Liss, et al., 1995 #1624
Townsend, Haggert, Liss, et al., 1995 #1624 | | | | | | | Black (n) | | | (33) | (32)
Townsend, Haggert, Liss, et al., 1995 #1624
Townsend, Haggert, Liss, et al., 1995 #1624 | | | | | | | Wk 4 | | | -6.5 | -3.3 | 0.02
Townsend, Haggert, Liss, et al., 1995 #1624
Townsend, Haggert, Liss, et al., 1995 #1624 | | | | | | | Wk 8 | | | -6.8 | -5.2 | 0.06
Townsend, Haggert, Liss, et al., 1995 #1624
Townsend, Haggert, Liss, et al., 1995 #1624 | | | | | | | Wk 12 | | | -10.0 | -8.0 | 0.02
Townsend, Haggert, Liss, et al., 1995 #1624
Townsend, Haggert, Liss, et al., 1995 #1624 | | | | | | | Non-black (n) | | | (99) | (104)
Townsend, Haggert, Liss, et al., 1995 #1624
Townsend, Haggert, Liss, et al., 1995 #1624 | | | | | | | Wk 4 | | | -8.4 | -7.0 | 0.10
Townsend, Haggert, Liss, et al., 1995 #1624
Townsend, Haggert, Liss, et al., 1995 #1624 | | | | | | | Wk 8 | | | -9.6 | -9.2 | 0.47
Townsend, Haggert, Liss, et al., 1995 #1624
Townsend, Haggert, Liss, et al., 1995 #1624 | | | | | | | Wk 12 | | | -10.4 | -10.4 | 0.51
Townsend, Haggert, Liss, et al., 1995 #1624
Townsend, Haggert, Liss, et al., 1995 #1624 | | | | | | | ≥ 65 yr | | | (25) | (30)
Townsend, Haggert, Liss, et al., 1995 #1624
Townsend, Haggert, Liss, et al., 1995 #1624 | | | | | | | Wk 4 | | | -9.0 | -6.4 | 0.06
Townsend, Haggert, Liss, et al., 1995 #1624
Townsend, Haggert, Liss, et al., 1995 #1624 | | | | | | | Wk 8 | | | -9.6 | -8.4 | 0.17
Townsend, Haggert, Liss, et al., 1995 #1624
Townsend, Haggert, Liss, et al., 1995 #1624 | | | | | | | Wk 12 | | | -12.7 | -10.1 | 0.03
Townsend, Haggert, Liss, et al., 1995 #1624
Townsend, Haggert, Liss, et al., 1995 #1624 | | | | | | | < 65 yr | | | (107) | (68)
Townsend, Haggert, Liss, et al., 1995 #1624
Townsend, Haggert, Liss, et al., 1995 #1624 | | | | | | | Wk 4 | | | -7.6 | -4.9 | 0.19
Townsend, Haggert, Liss, et al., 1995 #1624
Townsend, Haggert, Liss, et al., 1995 #1624 | | | | | | | Wk 8 | | | -8.7 | -8.6 | 0.06
Townsend, Haggert, Liss, et al., 1995 #1624
Townsend, Haggert, Liss, et al., 1995 #1624 | | | | | | | Wk 12 | | | -9.8 | -8.6 | 0.75
Townsend, Haggert, Liss, et al., 1995 #1624
Townsend, Haggert, Liss, et al., 1995 #1624 | | | | | | | 2) Rate of use of a single antihypertensive agent for BP control: Of 132 losartan patients, 62 (47%) received 50 mg losartan alone, 70 (53%) received 50 mg losartan + 12.5 mg HCTZ by end of study. Of 130 enalapril patients: 33 (24%) received 5 mg enalapril, 39(29%) were titrated to and continued taking 10 mg enalapril, and 64(47%) received 10 mg enalapril + 25 mg HCTZ by end of study. Between-group differences were not statistically significant. 3) Mortality: NR 4) Morbidity: NR 5) Safety: No lab test AEs were serious, no ECG AEs were serious 66% of enalapril patients had 1 or more AE 55% of losartan patients had 1 or more AE 35/132 losartan patients (27%) and 36/136 enalapril patients (26%) had a drug-related AE; no patient had a serious drug-related AE No statistically significant difference in the number of patients who withdrew due to an AE (9 losartan vs. 12 enalapril) 6) Specific adverse events: Most common AEs (losartan, enalapril): Headache: 10%, 15% Cough: 7%, 12% URI: 8%, 10% Dizziness: 5%, 7% Asthenia: 6%, 2% Drug-related AEs (losartan, enalapril): Cough: 4%, 10% Headache: 4%, 4% Dizziness: 2%, 3% Asthenia/fatigue: 27%, 26% 7) Persistence/adherence: NR 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Uchiyama-Tanaka, Mori, Kishimoto, et al., 2005 #1625 | Geographical location: Osaka, Japan Study dates: NR Funding source: NR Interventions:; - Quinapril 10 mg (n = 25); - Losartan 50 mg (n = 18); Dose titration and co-interventions: If BP not controlled at 2 mo, then given combination of 2 study drugs (i.e., quinapril 10 mg + losartan 50 mg) Study design: RCT, parallel-group Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: None Duration of treatment: 1 yr Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: 58; - Eligible for inclusion: NR; - Randomized: 57; - Began treatment: 57; - Completed treatment: NR; - Withdrawals/losses to followup: NR; Age: Mean (SD): 61 ± 9 Median: NR Range: NR Sex (n [%]): Female: 32 (56%) Male: 25 (44%) Race/ethnicity (n [%]): NR, but presumably 100% Asian Baseline blood pressure: Trough seated BP measured 3 times at 2-min intervals with patient resting using an automatic sphygmomanometer; average of 2 “most stable” readings used Baseline values (mean ± SD): | | | | | 1) Blood pressure: Quinapril vs. losartan results reported only for patients who achieved response on monotherapy Mean BP (± SD) at 1 yr (monotherapy responders only): | | | | | | General comments:; - Quinapril vs. losartan results reported only for patients who achieved response on monotherapy; - Open-label study allowing for bias in assessment; Quality assessment: Overall rating: Fair Comments:; - Recruitment and randomization not clearly described; - Open-label study allowing for bias in assessment of outcomes; - No data on safety/AEs or withdrawals; Applicability:; - Study location in single Japanese medical center; - No reporting on safety/AEs/withdrawals; - Quinapril vs. losartan results reported only for patients who achieved response on monotherapy
Uchiyama-Tanaka, Mori, Kishimoto, et al., 2005 #1625 | | | | | | | | | Quinapril alone [underlined: (n = 25)] | | Losartan alone [underlined: (n = 18)]
Uchiyama-Tanaka, Mori, Kishimoto, et al., 2005 #1625 | | | | | | | SBP | | 136 ± 7 | | 135 ± 6
Uchiyama-Tanaka, Mori, Kishimoto, et al., 2005 #1625 | | | | | | | DBP | | 78 ± 7 | | 76 ± 8
Uchiyama-Tanaka, Mori, Kishimoto, et al., 2005 #1625 | | | | | | | No significant difference between groups (p-value NR) 2) Rate of use of a single antihypertensive agent for BP control: 14/57 (25%) took combination quinapril and losartan due to inadequate BP control at 2 mo. Remainder (43/57 = 75%) stayed on monotherapy. 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels:
Uchiyama-Tanaka, Mori, Kishimoto, et al., 2005 #1625 | | | | | | | | | Quinapril monotherapy [underlined: (n = 25)] | | Lisinopril monotherapy [underlined: (n = 18)]
Uchiyama-Tanaka, Mori, Kishimoto, et al., 2005 #1625 | | | | | | | LDL baseline | | 134 (43) | | 121 (27)
Uchiyama-Tanaka, Mori, Kishimoto, et al., 2005 #1625 | | | | | | | LDL 1 yr | | 126 (27) | | 117 (31)
Uchiyama-Tanaka, Mori, Kishimoto, et al., 2005 #1625 | | | | | | | HDL baseline | | 56 (19) | | 49 (13)
Uchiyama-Tanaka, Mori, Kishimoto, et al., 2005 #1625 | | | | | | | HDL 1 yr | | 59 (20) | | 52 (16)
Uchiyama-Tanaka, Mori, Kishimoto, et al., 2005 #1625 | | | | | | | TG baseline | | 147 (56) | | 156 (73)
Uchiyama-Tanaka, Mori, Kishimoto, et al., 2005 #1625 | | | | | | | TG 1 yr | | 150 (69) | | 169 (55)
Uchiyama-Tanaka, Mori, Kishimoto, et al., 2005 #1625 | | | | | Quinapril alone [underlined: (n = 25)] | Losartan alone [underlined: (n = 18)] | None of the changes was statistically significant but no p-values reported Note: Patients taking antihyperlipidemia were not excluded, so cannot necessarily attribute lipid changes to study drugs 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control:
Uchiyama-Tanaka, Mori, Kishimoto, et al., 2005 #1625 | | SBP | | | 156 ± 14 | 156 ± 12 | | | Quinapril monotherapy [underlined: (n = 25)] | | Lisinopril monotherapy [underlined: (n = 18)]
Uchiyama-Tanaka, Mori, Kishimoto, et al., 2005 #1625 | | DBP | | | 92 ± 9 | 92 ± 10 | HgA1c baseline | | 5.5 (1.2) | | 5.4 (1.1)
Uchiyama-Tanaka, Mori, Kishimoto, et al., 2005 #1625 | | Concurrent medications (n [%]): NR Comorbidities (n [%]; n = 43 monotherapy responders): History of smoking: 17 (39.5%) History of diabetes: 11 (26%) History of hyperlipidemia: (37%) Recruitment setting: Outpatients attending renal and hypertension center at the university medical center Inclusion criteria:; - Untreated hypertension; - Diagnosed at the renal and htn center; - Mild-to-moderate essential hypertension accord to Japanese Society of Hypertension guidelines; Exclusion criteria:; - Signs, symptoms, or history of cardiac or renal disease, cerebrovascular accident, or any major disease; - Required anti-platelet or anticoagulation medications | | | | | HgA1c 1 yr | | 5.4 (1.0) | | 5.3 (1.5)
Uchiyama-Tanaka, Mori, Kishimoto, et al., 2005 #1625 | | | | | | | None of the changes was statistically significant but no p-values reported Note: Patients taking antidiabetes drugs were not excluded 11) LV mass/function: NR 12) Creatinine/GFR:
Uchiyama-Tanaka, Mori, Kishimoto, et al., 2005 #1625 | | | | | | | | | Quinapril monotherapy [underlined: (n = 25)] | | Lisinopril monotherapy [underlined: (n = 18)]
Uchiyama-Tanaka, Mori, Kishimoto, et al., 2005 #1625 | | | | | | | Cr baseline | | 0.6 (0.2) | | 0.7 (0.3)
Uchiyama-Tanaka, Mori, Kishimoto, et al., 2005 #1625 | | | | | | | Cr 1 yr | | 0.7 (0.3) | | 0.7 (0.2)
Uchiyama-Tanaka, Mori, Kishimoto, et al., 2005 #1625 | | | | | | | Cr reported in mg/dL None of the changes was statistically significant but no p-values reported 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | Geographical location: Perugia, Italy Study dates: NR Funding source: Supported in part by grants from the associzone umbra cuore e lapertensione, perugia, italy Interventions:; - Losartan 50 mg daily (n = 22); - Enalapril 20mg daily (n = 66); Dose titration/cointerventions: In both groups, HCTZ 25 mg daily added if needed (SBP ≥ 140 or DBP > 90) Study design: Case-control selected from observational registry (n = 701) Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: No; Was allocation concealment adequate?: No randomization Baseline/run-in period: NA Duration of treatment: Average of 3.3 yr Duration of post-treatment followup: NA | Number of patients:; - Screened for inclusion: 701 (from cohort); - Eligible for inclusion: NR; - Randomized: NA; - Began treatment: 108; - Completed treatment: 88; - Withdrawals/losses to followup: 20 (14 due to AEs, 6 for unspecified reasons); Age: Mean (SD): NR Median: NR Range: NR Sex (n [%]): Female: 50% Male: 50% Race/ethnicity (n [%]): NR Baseline blood pressure: Seated trough office BP assessed using a standard mercury sphygmanometer; mean of 3 measurements taken after subject rested for 10 min | | | | | 1) Blood pressure: Mean trough seated BP on treatment (avg. 3.3 yr): | | | | | | General comments:; - Baseline characteristics of patients NR; Quality assessment: Overall rating: Poor Comments:; - No baseline characteristics reported; - No detail about extent of followup (only give average of 3.3 yr); Applicability:; - No baseline patient characteristics described or compared; - Little detail about selection of case-controls, reasons for exclusion from eligible patients; - Duration of therapy not defined at all
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | | | [underlined: Losartan] | | [underlined: Enalapril]
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | SBP | | 140 ± 14 | | 140 ± 18
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | DBP | | 90 ± 8 | | 87 ± 7
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | All pre-/post- differences p < 0.01 Between-group p-values NR Also report 24-hr ABPM data 2) Rate of use of a single antihypertensive agent for BP control: Number of patients (%) not taking adjunctive HCTZ: Losartan: 12 (55%) Enalapril: 32 (48%) 3) Mortality: NR 4) Morbidity: NR 5) Safety: Withdrawals due to AEs: Losartan: 2 (headache, gastric distress) Enalapril: 12 (all cough) 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: Mean total cholesterol (mmol/L):
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | [underlined: Losartan] | [underlined: Enalapril] | | | | [underlined: Baseline] | [underlined: Followup] | [underlined: p-value]
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | SBP | | | 155 ± 14 | 155 ± 15 | Losartan | | | 5.09 ± 0.79 | 5.23 ± 0.86 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | DBP | | | 100 ± 9 | 99 ± 9 | Enalapri | | | 5.51 ± 0.93 | 5.92 ± 0.92 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting:; - from PIUMA (Progetto Ipertensione Umbria Monitoaggio Ambulatoriale) study [ref 4, 14 in paper]; Inclusion criteria:; - Office SBP ≥ 140 and/or DBP ≥ 90 on ≥ 3 visits; - ≥1 valid BP measurement within 24h before enrollment; Exclusion criteria:; - Previous antihypertensive therapy or drugs withdrawn from ≥ 4 wk; - Evidence of CHF, CAD, significant valvular defects; - Secondary causes of HTN; - “Other concomitant important disease” | | | | | Mean HDL cholesterol (mmol/L):
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | | | | [underlined: Baseline] | [underlined: Followup] | [underlined: p-value]
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | Losartan | | | 1.26 ± 0.30 | 1.30 ± 0.21 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | Enalapril | | | 1.24 ± 0.28 | 1.28 ± 0.32 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | Mean LDL cholesterol (mmol/L):
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | | | | [underlined: Baseline] | [underlined: Followup] | [underlined: p-value]
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | Losartan | | | 3.42 ± 0.79 | 3.32 ± 0.82 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | Enalapril | | | 3.59 ± 0.85 | 3.77 ± 0.86 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | Mean triglycerides (mmol/L):
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | | | | [underlined: Baseline] | [underlined: Followup] | [underlined: p-value]
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | Losartan | | | 1.23 ± 0.49 | 1.34 ± 0.56 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | Enalapril | | | 1.47 ± 0.78 | 1.78 ± 0.86 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: Mean glucose (mmol/L):
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | | | | [underlined: Baseline] | [underlined: Followup] | [underlined: p-value]
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | Losartan | | | 5.36 ± 0.65 | 5.31 ± 0.61 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | Enalapril | | | 5.56 ± 0.88 | 5.61 ± 0.90 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | 11) LV mass/function: LV mass (g/BSA [m^2^]):
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | | | | [underlined: Baseline] | [underlined: Followup] | [underlined: p-value]
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | Losartan | | | 98 ± 18 | 87 ± 19 | <0.001
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | Enalapril | | | 98 ± 20 | 89 ± 20 | <0.001
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | Similar results with LV mass in g/height Also report multiple other echo measurements including - IVS thickness, LV internal diam, PW thickness, endocardial shortening fraction, midwall shortening fraction, peak E/A ratio 12) Creatinine/GFR: Mean creatinine (mmol/L):
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | | | | [underlined: Baseline] | [underlined: Followup] | [underlined: p-value]
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | Losartan | | | 85.7 ± 10.4 | 83.9 ± 12.9 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | Enalapril | | | 82.8 ± 14.7 | 93.2 ± 75.6 | NS
Verdecchia, Schillaci, Reboldi, et al., 2000 #1626 | | | | | | | Note - SD for enalapril on f/u must be a typo 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Veronesi, Cicero, Prandin, et al., 2007 #148 | Geographical location: Bologna, Italy Study dates: NR Funding source: NR Interventions: Randomized to:; - ACEI (n = 61); - ARB (n = 53); - Calcium channel blocker (n = 63); - Diuretic (n = 63); - Beta-blocker (n = 61); Sample sizes above are for patients who completed the study. Number of patients initially allocated to each drug class was NR. Name and dosage of medications NR Were additional anti-hypertension medications allowed: Yes; combination treatment was used in 15/347 patients (4%) If Yes to above, was this done: Per protocol (second medication [class NR] added if < 10% reduction of SBP by monotherapy after 6 months of treatment Study design: RCT, parallel-group Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: No; Was allocation concealment adequate?: No Baseline/run-in period: None Duration of treatment: 24 months Duration of post-treatment followup: None; last followup after 24 months of treatment | Number of patients: N = 347; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: NR; - Began treatment: NR; - Completed treatment: 347; - Withdrawals/losses to followup: NR; Age: Mean (SD): 59.4 ±6 Sex (n [%]): Female: 141 (40.6%) Male: 206 (59.4%) Race/ethnicity (n [%]): NR Baseline blood pressure: Resting and supine by mercury sphygmomanometer, mean of 3 readings 1 minute apart. | | | | | 1) Blood pressure: Change (by inference, time of second BP reading was at the 24 month followup) | | | | | | General comments:; - No information reported on number of patients enrolled, number randomized, number of withdrawals, or reasons for loss to followup or exclusion after enrollment; - No details on names and dosages of study medications, thereby making it impossible to interpret potential therapeutic dosages of study medications; Quality assessment: Overall rating: Poor Comments:; - Inadequate reporting in many areas, including patient characteristics, patient flow (including screening, randomization, and withdrawal information) and name and dosages of study medications; - Unblinded study; Applicability:; - Poor generalizability due to inadequate reporting of patient population, interventions, and results; - Insufficient details about study medications, including name and dosage; - Insufficient reporting about comorbidities and cointerventions
Veronesi, Cicero, Prandin, et al., 2007 #148 | | | | | | | | | [underlined: ACEI] | | [underlined: ARB]
Veronesi, Cicero, Prandin, et al., 2007 #148 | | | | | | | SBP: | | -10.5 | | -11.2
Veronesi, Cicero, Prandin, et al., 2007 #148 | | | | | | | DBP: | | -5.1 | | -5.8
Veronesi, Cicero, Prandin, et al., 2007 #148 | | | | | | | No statistically significant difference between classes of drugs. 2) Rate of use of a single antihypertensive agent for BP control: 78.1% of entire sample (breakdown by drug class NR) 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: Persistence with antihypertensive treatment defined as the continued use of medications according to initial prescription over the period of followup. In patients in whom treatment was discontinued before the end of followup, persistence quantified as the time interval between randomization and treatment discontinuation. “Not persistent” patients included those who withdrew from treatment or those who were switched to a different class of drugs After 24 months: ACEI: 64.5% ARB: 68.5% No statistically significant difference between classes of antihypertensives Mean duration of persistence: ACEI: 18.7 ± 8 months ARB: 20.3 ± 9 months In logistic regression model of persistence on treatment using ARBs as referent, patients taking ACEIs were more likely to continue their initial antihypertensive therapy: OR 0.94; 95% CI 0.79 to 0.99 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR
Veronesi, Cicero, Prandin, et al., 2007 #148 | | | | | [underlined: ACEI] | [underlined: ARB]
Veronesi, Cicero, Prandin, et al., 2007 #148 | | SBP: | | | 152.5 ± 12 | 154.3 ± 13
Veronesi, Cicero, Prandin, et al., 2007 #148 | | DBP: | | | 98.7 ± 8 | 99.1 ± 7
Veronesi, Cicero, Prandin, et al., 2007 #148 | | Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria:; - Uncomplicated mild to moderate HTN (SBP 140-159 mmHg and DBP 90-109 mmHg); - Age > 8 and ≤ 80; - No antihypertensive treatment during last 6 months; - No history of major cardiovascular diseases (previous stroke, MI, heart failure, major arrhythmias) requiring complex pharmacological treatment; - No history of intolerance or hypersensitivity for specific classes of antihypertensive drugs; - Lack of compelling indications for a specific class of antihypertensive drugs according to ESH-ESC Guidelines (ESH-ESC 2003); - Capacity to comply with study protocol; Exclusion criteria:; - Secondary causes of HTN; - Patients who needed a 3^rd^ drug to control HTN were excluded from analysis after enrollment

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Williams, Gosse, Lowe, et al., 2006 #296 | Geographical location: 75 centers Austria, France, Germany, Netherlands, South Africa, Spain, Switzerland, and United Kingdom Study dates: NR Funding source: NR Interventions:; - Telmisartan 40 mg initial dose and forced titration to 80 mg after 2 wk (n = 397); - Ramipril 5 mg for 8 wk and then force titrated to ramipril 10 mg for the last 6 wk (n = 404); Study design: RCT, parallel-group Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: Yes; Was allocation concealment adequate?: NR Baseline/run-in period: 2- to 4-wk single-blind placebo run-in phase in which prior antihypertensives were discontinued Duration of treatment: 14 wk Duration of post-treatment followup: NR | Number of patients:; - Screened for inclusion: 1593; - Eligible for inclusion: 801; - Randomized: 801; - Began treatment: 801; - Completed treatment: 714; - Withdrawals/losses to followup: 57, 37 due to AEs, 10 due to lack of efficacy, 10 withdrew consent (note: reported numbers do not total correctly); Age: Mean (SD): 53.6 (10.6) ≥ 65: 131 (16%) Sex (n [%]): Female: 322 (41.2%) Male: 479 (59.8) Race/ethnicity (n [%]): White 621 (77.5%) Black 14 (1.7%) Mongoloid 7 (0.9%) Missing 159 (19.9%) Baseline blood pressure: Seated trough BP measured in triplicate using a manual sphygmomanometer according to ASH guidelines | | | | | 1) Blood pressure: Changes in trough seated BP from baseline to 14 wk: Reductions were greater with telmisartan 80 mg than with ramipril 10 mg by 4.6 mm Hg for SBP (p < 0.0001) and by 2.2 mm Hg for DBP (p = 0.0002). Pre-/post-treatment mean values NR. Seated DBP response (DBP < 90 mm Hg or reduction from baseline of ≥ 10 mm Hg): Telmisartan: 61.9% Ramipril: 54.8% (p = 0.03) Seated SBP response (SBP < 140 mm Hg or reduction from baseline of ≥ 10 mm Hg): Telmisartan: 76.2% Ramipril: 66.9% (p = 0.004) DBP response defined as DBP < 90 mm Hg or reduction from baseline ≥ 10 mm Hg; SBP response defined as SBP < 140 or reduction ≥ 10 Also report BP in last 6 hours of 24 hours of ABPM at 14 weeks, as follows: | | | | | | General comments:; - Titrations at different times so that telmisartan is titrated up and to higher relative dose than ramipril; - No discussion outside of forced titration of BP checks during study and if any additional agents or if SBP very high what was done; Quality assessment: Overall rating: Fair Comments:; - No clear concealment of randomization; - Not blinded; - Titrated drugs at different times; Applicability: Excludes so many patients that patients with heart disease or patients with many comorbidities would be excluded from the trial
Williams, Gosse, Lowe, et al., 2006 #296 | | | | | [underlined: Telmisartan] | [underlined: Ramipril] | | | [underlined: Telmisartan] | | [underlined: Ramipril]
Williams, Gosse, Lowe, et al., 2006 #296 | | SPB | | | 158.5 ± 11.9 | 158.3 ± 12.5 | SBP (SD) | | 128.7 (15.4) | | 132.7 (14.8)
Williams, Gosse, Lowe, et al., 2006 #296 | | DBP | | | 100.1 ± 4.9 | 100.1 ± 4.9 | SBP change (SD) | | -11.5 (11.7) | | -8.2 (8.3)
Williams, Gosse, Lowe, et al., 2006 #296 | | Concurrent medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: Clinic setting Inclusion criteria:; - Age ≥ 18; - Mean seated DBP of 95-109 mm Hg measured using a manual sphygmomanometer (mean of 3 measurements taken 2 min apart); - 24-hr ABP of DBP ≥ 85 mm Hg after run-in period; Exclusion criteria:; - Known or suspected history of coronary disease, stroke, congestive heart failure, or recent acute cardiovascular event, secondary hypertension, poorly controlled insulin-dependant diabetes mellitus, or chronic kidney disease; - Premenopausal women not using adequate contraception; - Night shift workers | | | | | DBP (SD) | | 79.6 (9.3) | | 81.7 (9.1)
Williams, Gosse, Lowe, et al., 2006 #296 | | | | | | | DBP change (SD) | | -8.2 (8.3) | | -5.4 (7.7)
Williams, Gosse, Lowe, et al., 2006 #296 | | | | | | | Adj. SBP change^*^ (SEM) | | -12.1 (.65) | | -8.4 (.64)
Williams, Gosse, Lowe, et al., 2006 #296 | | | | | | | Adj. DBP change^*^ (SEM) | | -8.5 (.44) | | -5.8 (.43)
Williams, Gosse, Lowe, et al., 2006 #296 | | | | | | | ^*^From model including main effects of treatment and 24 hr BP monitoring
Williams, Gosse, Lowe, et al., 2006 #296 | | | | | | | SBP difference (SEM) (telmisartan-ramipril): -3.7; SEM: 0.85; 95% CI: -5.4 to -2.0; P < 0.0001 DBP difference (SEM) (telmisartan-ramipril): -2.7; SEM: 0.57; 95% CI: -3.8 to -1.5; P < 0.0001 “Per-protocol analysis of the reduction from baseline in DBP confirmed that telmisartan 80 mg was superior to ramipril 5 mg (p < 0.0001) and 10 mg (p < 0.0001) in reducing the last 6-hour mean ambulatory DBP.” 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: There were no deaths during the study. 4) Morbidity: NR 5) Safety: Any AE: Telmisartan: 153/397 (38.5%) Ramipril: 162/404 (40.1%) Severe AEs: Telmisartan: 13 (3.3%) Ramipril: 17 (4.2%) Drug-related AEs: Telmisartan: 6.5% Ramipril: 10.1% Drug-related serious AEs: 0 6) Specific adverse events: Drug-related AEs with incidence greater than 1% (fatigue, dizziness, HA, and cough) occurred in 14 (3.5%) telmisartan vs. 23 (5.7%) ramipril patients Cough: 2 (0.5%) telmisartan vs. 23 (5.7%) ramipril 7) Persistence/adherence: Adherence monitored at each visit by counting the number of returned tablets. Noncompliant patients discontinued from rest of study but included in ITT analysis. Compliance with treatment was high (> 98.8%) in both groups – recognize this is in 714/801 patients that completed study 5 patients in each group withdrew because of lack of efficacy 21 in the telmisartan and 16 in the ramipril group withdraw because of AEs 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Wogen, Kreilick, Livornese, et al., 2003 #1627 | Geographical location: U.S. (“geographically diverse” claims database) Study dates: Aug 1998 – Jul 2000 Funding source: Novartis Pharmaceuticals, Inc. Interventions: Lisinopril (n = 40,238) Valsartan (n = 29,669) Amlodipine (n = 73,148) Study design: Retrospective cohort study Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: No; Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: NA Duration of post-treatment followup: 1 yr | Number of patients:; - Screened for inclusion: 14.6 million; - Eligible for inclusion: 142,945; - Randomized: NA; - Began treatment: 142,945; - Completed treatment: NA; - Withdrawals/losses to followup: NA; Age: Mean (SD): 63.1 (14.0) Median: NR Range: NR Sex (n [%]): Female: 53% Male: 47% Race/ethnicity (n [%]): NR; database stated to be “demographically diverse” Baseline blood pressure: NR Concurrent medications (n [%]): Concurrent cardiovascular meds: Diuretics: 35% Antihyperlipidemics: 32% Beta-blockers: 25.5% Antiplatelets: 14% Nitrates: 15% Digitalis: 9% Diuretic combination: 8% Valsartan patients significantly less likely to be prescribed these meds than patients in other two groups. Comorbidities (n [%]): Mean Chronic Disease Score (± SD) was 10.15 ± 6.00 for the entire cohort and was essentially comparable for all groups A significantly smaller proportion of valsartan patients was classified as having a “severe” chronic disease burden (35% vs. 31% for both lisinopril and amlodipine; p < 0.0001) Recruitment setting: Administrative pharmacy claims database from a large pharmacy benefits manager. Described as a “demographically and geographically diverse database that contains 3 years of longitudinal pharmacy claims data representing the payer mix in the U.S. health care market, including drug-insured lives from health care insurance carriers, managed care organizations, employers, and retirement and government plans.” Inclusion criteria:; - Continuously benefit-eligible for both mail-order and community pharmacy prescriptions between 1 Aug 1997 and 31 Jul 2000; - Initial prescription for one of 3 study drugs between 1 Aug 1998 and 31 Jul 1999; - New to therapy within the drug class (patients who received a prescription for a drug from the same class in the preceding 12 mo were excluded); Exclusion criteria: None specified | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: Discontinuation was defined as a 60+ day period without a new prescription; persistence was defined as the absence of discontinuation. Discontinuation was examined directly and also in a Cox model that controlled for age, sex, chronic disease burden, and use of other antihypertensive agents. The results of this modeling were similar to the unadjusted results. Compliance was not measured directly, but instead was estimated as the total days' supply of all prescriptions divided by the length of therapy. Predictors of non-compliance included older age, female sex, high chronic disease scores, use of lipid medications, use of beta-blockers, and use of nitrates. | | | | | | General comments: None Quality assessment: Overall rating: Fair Comments:; - Non-random allocation to drugs; - Differences noted in comorbidity between valsartan-treated patients and those on other antihypertensive drugs; - Funded by pharmaceutical company; Applicability:; - Study period soon after introduction of ARBs; early use may not reflect current use patters
Wogen, Kreilick, Livornese, et al., 2003 #1627 | | | | | | | | | [underlined: 1-yr persistence] | | [underlined: Compliance]
Wogen, Kreilick, Livornese, et al., 2003 #1627 | | | | | | | Lisinopril | | 50% | | 86.3%
Wogen, Kreilick, Livornese, et al., 2003 #1627 | | | | | | | Valsartan | | 63% | | 88.5%
Wogen, Kreilick, Livornese, et al., 2003 #1627 | | | | | | | Amlodipine | | 53% | | 86.7%
Wogen, Kreilick, Livornese, et al., 2003 #1627 | | | | | | | 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Xu, Liu, Ji, et al., 2007 #1288 | Geographical location: China Study dates: Jan-Dec 2006 Funding source: NR Interventions: Telmisartan 80 mg/day (n = 46) Enalapril 10 mg/day (n = 50) Were additional anti-hypertension medications allowed: NR Study design: RCT, parallel-group Blinding:; - Patients: NR; - Providers: NR; - Assessors of outcomes: NR; Was allocation concealment adequate?: NR Baseline/run-in period: NR Duration of treatment: 6 months Duration of post-treatment followup: No followup after 6 months reported | Number of patients: N = 96; - Screened for inclusion: NR; - Eligible for inclusion: NR; - Randomized: 96; - Began treatment: 96; - Completed treatment:94; - Withdrawals/losses to followup: 2 in enalapril group for cough; Age: Mean (SD): 51.2 ± 9.6 Range: 42 - 65 Sex (n [%]): Female: 34 (35.4%) Male: 62 (64.6%) Race/ethnicity (n [%]): NR Baseline blood pressure: Sitting blood pressure was measured in the right upper brachial artery for 3 times with an appropriate mercury sphygmomanometer, after at least 10 minutes of rest Telmisartan: SBP(mmHg) 149.24 ± 5.02 DSP (mmHg) 98.2 ± 7.20 Enalapril: SBP(mmHg) 148.6 ± 4.43 DSP (mmHg) 99.12 ± 2.97 Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: NR Inclusion criteria: Hypertensive outpatients with abnormal blood lipids according to WHO standard Exclusion criteria:; - Secondary HTN; - Renal insufficiency; - DM; - Acute coronary syndrome | | | | | 1) Blood pressure: [underlined: SBP (mmHg):] Telmisartan: Pre-therapy: 149.2 ± 5.02 3 months: 136.3 ± 4.7 6 months: 135.9 ± 3.9 Enalapril: Pre-therapy: 148.6 ± 4.4 3 months: 137.0 ± 5.1 6 months: 136.0 ± 7.0 [underlined: DBP (mmHg):] Telmisartan: Pre-therapy: 98.2 ± 7.2 3 months: 90.0 ± 2.8* 6 months: 88.1 ± 3.0 Enalapril: Pre-therapy: 99.1 ± 3.0 3 months: 89.3 ± 3.0 6 months: 87.2 ± 4.1 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: None 4) Morbidity: NR 5) Safety: Cough reported in 2 patients in enalapril group significant enough to cause withdrawal. No other adverse events reported. 6) Specific adverse events: Cough reported in 2 patients in enalapril group significant enough to cause withdrawal. No other adverse events reported. 7) Persistence/adherence: Except for 2 patients described above, all other patients completed 6 months of treatment 8) Lipid levels: [underlined: Total cholesterol (TC; mmol/L):] Telmisartan: Pre-therapy: 6.1 ± 1.9 3 months: 6.0 ± 0.7 6 months: 5.8 ± 0.8 Enalapril: Pre-therapy: 6.1 ± 1.0 3 months: 6.0 ± 1.1 6 months: 5.9 ± 1.1 [underlined: Triglycerides (TG; mmol/L):] Telmisartan: Pre-therapy: 2.8 ± 1.2 3 months: 2.4 ± 0.8 6 months: 2.0 ± 0.6 Enalapril: Pre-therapy: 2.8 ± 1.0 3 months: 2.7 ± 0.9 6 months: 2.6 ± 0.9 [underlined: LDL cholesterol (mmol/L):] Telmisartan: Pre-therapy: 3.1 ± 0.8 3 months: 2.7 ± 1.0 6 months: 2.3 ± 0.9 Enalapril: Pre-therapy: 3.1 ± 1.0 3 months: 2.7 ± 1.0 6 months: 2.3 ± 0.9 [underlined: HDL cholesterol (mmol/L):] Telmisartan: Pre-therapy: 1.4 ± 0.7 3 months: 1.5 ± 0.9 6 months: 1.65 ± 0.9 Enalapril: Pre-therapy: 1.4 ± 0.7 3 months: 1.4 ± 0.8 6 months: 1.4 ± 1.0 The level of TG in the telmisartan group decreased obviously after 3-month treatment compared with that of pre-therapy and the enalapril group (P < 0.05), and the level of TG decreased more significantly after 6-month treatment (P < 0.01). The level of HDL cholesterol was significantly higher after 6-month treatment in the telmisartan group than pre-therapy and in the enalapril group (P < 0.05). 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: [underlined: Fasting blood glucose (mmol/L):] Telmisartan: Pre-therapy: 4.5 ± 0.5 3 months: 4.6 ± 0.5 6 months: 4.6 ± 0.6 Enalapril: Pre-therapy: 4.6 ± 0.5 3 months: 4.7 ± 0.5 6 months: 4.7 ± 0.5 [underlined: HOMA-IS (mU/L):] Telmisartan: Pre-therapy: 2.2 ± 0.4 3 months: 1.9 ± 0.3 6 months: 1.6 ± 0.3 Enalapril: Pre-therapy: 2.1 ± 0.3 3 months: 2.0 ± 0.3 6 months: 2.0 ± 0.3 HOMA-IS and HOMA-IR in the telmisartan group were significantly lower than pre-therapy and in the enalapril group after 3-month treatment (P < 0.05). HOMA-IS, HOMAIR, and P2HBG in the telmisartan group decreased significantly after 6-month treatment compared with pre-therapy and with the enalapril group (P < 0.01, P < 0.01, P < 0.05). HOMA-IS and HOMA-IR in the telmisartan group were lower after 6- month treatment than they were after 3-month treatment (P < 0.05). 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | | General comments: None Quality assessment: Overall rating: Poor Comments: No information about other medications, how randomization was done, or AEs that did not cause withdrawals Applicability:; - No information about randomization process or blinding; - No information about comorbidities or use of other medications

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Yilmaz, Sonmez, Caglar, et al., 2007 #212 | Geographical location: Etlik-Ankara, Turkey Study dates: 2004-2006 Funding source: NR Interventions:; - Metoprolol 100 mg (n = 18); - Amlodipine 10 mg (n = 20); - Doxazosin 4 mg (n = 18); - Ramipril 5 (n = 20); - Valsartan 80 mg (n = 20); Were additional anti-hypertension medications allowed: No (not explicitly stated, but implied) Study design: RCT, parallel-group Blinding:; - Patients: No; - Providers: No; - Assessors of outcomes: NR; Was allocation concealment adequate?: No. “…we stratified patients according to the above parameters [age, gender, BMI] in to similar groups and then assigned each group one of the study drugs” Baseline/run-in period: Up to 3 weeks of observation. Whether any patients became ineligible during the run-in period is NR. Duration of treatment: 3 months Duration of post-treatment followup: None (last followup at end of 3-month treatment) | Number of patients: N = 96; - Screened for inclusion: 224; - Eligible for inclusion: NR; - Randomized: 96; - Began treatment: 96; - Completed treatment: 96; - Withdrawals/losses to followup: 0 (but whether some patients discontinued treatment was NR); Ambiguous reporting of how many patients began and completed the run-in period Age: Mean (SD): 47.88 ± 5.29 Sex (n [%]): Female: 48 (50%) Male: 48 (50%) Race/ethnicity (n[%]): NR Baseline blood pressure: Mean of 3 arm BP cuff readings in the morning in a resting condition. Ramipril: SBP 152.60 (SD 8.92) DBP 93.20 (SD 3.27) Valsartan SBP 157.55 (SD 7.08) DBP 94.60 (SD 3.40) Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: Referred by outpatient nephrology clinics Inclusion criteria: HTN (SBP ≥ 140 mmHg, DBP ≥ 90 mmHg) and at least 2 of the following: high triglycerides (> 150 mg/dL); low HDL (< 40 mg/dL for men and < 50 for women); high blood glucose > 100 mg/dL; high waist circumference (> 102 for men and > 88 for women) Exclusion criteria:; - Currently taking any drugs including supplemental vitamin tablets and OTC drugs; - Coronary artery disease (history of revascularization, ischemic ST segment alterations, or ECG criteria for left ventricular hypertrophy); - Diabetes mellitus; - Serum creatinine > 1.2 mg/dL | | | | | 1) Blood pressure: [underlined: BP at 3 months:] Ramipril: SBP 136.10 (SD 5.09) DBP 87.65 (SD 3.80) Valsartan SBP 129.70 (SD 8.12) DBP 85.55 (SD 4.35) 2) Rate of use of a single antihypertensive agent for BP control: NR (by inference, all patients were prescribed a single antihypertensive agent) 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: NR 8) Lipid levels: [underlined: Baseline (mmol/L [SD]):] Ramipril: Triglycerides: 8.78 (1.86) Total cholesterol: 14.31 (2.16) LDL: 7.34 (1.45) HDL: 2.01 (0.30) Valsartan Triglycerides: 10.95 (3.19) Total cholesterol: 14.90 (2.29) LDL: 7.74 (2.02) HDL: 1.92 (0.25) [underlined: At 3-mo followup (mmol/L [SD])]: Ramipril: Triglycerides: 7.57 (1.95) Total cholesterol: 11.97 (1.83) LDL: 5.47 (1.06) HDL: 2.37 (0.32) Valsartan Triglycerides: 8.87 (2.39) Total cholesterol: 12.57 (2.50) LDL: 6.09 (1.85) HDL: 2.32 (0.29) P < 0.05 for all changes from baseline within groups, but comparison between groups was not reported 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: [underlined: Baseline:] Ramipril: Adiponectin (microgram/L [SD]): 9.38 (2.61) Insulin (mircoU/mL [SD]): 6.88 (1.08) HOMA: 1.59 (0.71) Fasting glucose (mmol/L [SD]): 5.22 (0.46) Valsartan: Adiponectin (microgram/L [SD]): 8.50 (2.60) Insulin (mircoU/mL [SD]): 6.83 (1.26) HOMA: 1.60 (0.83) Fasting glucose (mmol/L [SD]): 5.38 (0.44) [underlined: At 3-month followup:] Ramipril: Adiponectin (microgram/L [SD]): 14.54 (3.82) Insulin (mircoU/mL [SD]): 5.80 (0.93) HOMA: 1.33 (0.54) Fasting glucose (mmol/L [SD]): 1.33 (0.54) Valsartan: Adiponectin (microgram/L [SD]): 14.40 (3.19) Insulin (mircoU/mL [SD]): 5.07 (1.42) HOMA: 1.15 (0.73) Fasting glucose (mmol/L [SD]): 5.11 (0.47) 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | | General comments:; - Sample drawn from nephrology clinics that referred patients with metabolic syndrome who had not previously received treatment; - Patients reportedly were unaware that they had HTN; - Screening process and results not adequately reported; - Final sample may not be representative of a larger clinical population; Quality assessment: Overall rating: Poor Comments:; - Unblinded; - Randomization protocol poorly described; - Small sample size; - Poor reporting of outcomes by drug; Applicability:; - Inadequate description of patient population; - Inadequate reporting of patient flow and co-interventions

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Yokoyama, Yang, Preblick, et al., 2007 #210 | Geographical location: 4 commercial managed care health plans located in Northeast, Midwest, and Western US. Study dates: May 1, 2001, to Feb 28, 2003 Funding source: Novartis Pharmaceuticals Corp. Interventions: Comparison of step-therapy program in 3 health plans in which a claim for an ARB triggered an electronic search of the patient's data for either an ACEI or an ARB in the preceding 3 months. The ARB claim was rejected if there was no prior use of ACEI/ARB in this timeframe and either pharmacist or patient had to contact prescriber to obtain an alternative to the ARB or a prior authorization (e.g., evidence that patient had attempted ACEI previously). The comparison group did not have a step-therapy program and used a tiered co-payment system Were additional anti-hypertension medications allowed: Yes If Yes to above, was this done: At discretion of clinician/investigator Study design: Other – retrospective cohort study Blinding: No Was allocation concealment adequate?: NA Baseline/run-in period: NA Duration of treatment: Minimum 12-month followup data Duration of post-treatment followup: NA | Number of patients: STEP therapy cohort N = 6758; - Screened for inclusion: 1,000,000; - Eligible for inclusion: 6758; - Randomized: NA; - Began treatment: 6758; - Completed treatment: NA; - Withdrawals/losses to followup: NA; Comparison cohort N = 33,709; - Screened for inclusion: 2,000,000; - Eligible for inclusion: 33,709; - Randomized: NA; - Began treatment: 33,709; - Completed treatment: NA; - Withdrawals/losses to followup: NA; Age: Step therapy cohort: Mean (SD): 52.9 (11.2) Comparison group: Mean (SD): 57.6 (13.4) Sex (n [%]): Step therapy cohort: Male: 3652 (54.0) Female: 3106 (46.0) Comparison group: Female: 15355 (45.6) Male: 18354 (54.4) Race/ethnicity (n [%]): NR Baseline blood pressure: NR Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): Chronic disease score (SD): Step-therapy: 1598.3 (2089.83) Comparison: 1860.95 (2300.41) Recruitment setting: Pharmacy claims data from 4 health plans Inclusion criteria: Step therapy cohort selection:; - Members from one of 3 participating health plans with step therapy; - Age ≥ 18 years; - Either started on an ACEI or were rejected for ARB during 6-month identification period; - Continuously enrolled in the 3 months prior to and 12 months following the index date; - No ACEI or ARB claims in the 3 months preceding new start; Comparison group selection:; - Members of the participating health plan; - Age ≥ 18 years; - Started on either an ACEI or an ARB during 6-month identification period; - Continuously enrolled in the 3 months prior to and 12 months following the index date; - No ACEI or ARB claims in the 3 months preceding new start | | | | | 1) Blood pressure: NR 2) Rate of use of a single antihypertensive agent for BP control: Rates of monotherapy reported, but comparison is between stepped care and comparison (not ACE vs. ARB) 3) Mortality: NR 4) Morbidity: NR 5) Safety: NR 6) Specific adverse events: NR 7) Persistence/adherence: Among patients initiated on ACEI, proportion who switch to [underlined: or added] ARB within 12 months: Step care group: 333/5462 (6.1%) Comparison: 1811/25012 (7.2%) Note, no information given on switch to other medication classes, so likely underestimates switch rate to other medicine Of those whose ARB request was denied and who were instead given an ACEI, proportion switching to ARB within 12 months (combining ACE mono and combo therapy): 54/192 (28%) 8) Lipid levels: NR 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: NR 11) LV mass/function: NR 12) Creatinine/GFR: NR 13) Proteinuria: NR | | | | | | General comments: Cost data was also reported Quality assessment: Overall rating: Poor Comments: None Applicability:; - Low-quality pharmacy claims data that does not capture current or prior adverse reactions, reasons for switching, or relevant comorbidities; - Authors reported switch results as “switch to [underlined: or added] ARB” (emphasis ours); - Nearly ½ of denied ARB claims were overturned and patient received ARB. Some of these patients may have been ACEI-intolerant, but not captured in database records

Study | Interventions and study design | Patient characteristics | | | | | Results | | | | | | Comments/quality/applicability
Zhu, Liu, Wang, et al., 2008 #1220 | Geographical location: Jinan, People's Republic of China Study dates: Recruited June to Dec 2006 Funding source: This work was supported by Jinan Science and Technology Research Foundation, Jinan, China Interventions:; - Benazepril 10 mg once daily (n = 30); - Valsartan 80 mg once daily (n = 30); - Benazepril 10 mg + valsartan 80 mg once daily (n = 30); Doses of medications were doubled after 2 weeks if BP > 140/90 Were additional anti-hypertension medications allowed: Yes If Yes to above, was this done: Per protocol (HCTZ added if BP not at goal after dose escalation) Study design: RCT, parallel-group, double-blind Blinding:; - Patients: Yes; - Providers: Yes; - Assessors of outcomes: Yes; Was allocation concealment adequate?: NR Baseline/run-in period: 1 week Duration of treatment: 12 weeks Duration of post-treatment followup: NA | Number of patients: N = 90; - Screened for inclusion: 156; - Eligible for inclusion: 90; - Randomized: 90; - Began treatment: 90; - Completed treatment: 82; - Withdrawals/losses to followup: 8 lost to follow up; Age: Mean (SD): Benazepril: 55 ± 11 Valsartan: 57 ± 10 Sex (n [%]): Female: 12/28 (benazepril), 11/27 (valsartan) Male: 16/28 (benazepril), 16/27 (valsartan) Race/ethnicity (n [%]): NR Baseline blood pressure: Blood pressure was taken as the mean of two to three independent measurements with at least 2-min separation obtained with a standard sphygmomanometer after 5 min of rest at clinic. A 24-h ambulatory blood pressure monitoring was also applied to record SBP and DBP for those who were admitted to the antihypertensive drug trial at baseline and 12 weeks. Benazepril: SBP (mmHg) 153 ± 11 DBP (mmHg) 95 ± 12 Valsartan: SBP (mmHg) 151 ± 10 DBP (mmHg) 93 ± 10 Concurrent non-hypertension medications (n [%]): NR Comorbidities (n [%]): NR Recruitment setting: All participants were recruited at Jinan Central Hospital Clinic Inclusion criteria: Stages 1 (SBP 140–159 mmHg and DBP 90–99 mmHg) and 2 (SBP 160–179 mmHg and DBP 100–109 mmHg) essential hypertension Exclusion criteria:; - Infectious and inflammatory diseases; - Presence of any form of secondary HTN; - Heart failure with LVH; - Diabetes mellitus; - Metabolic disease; - Hepatic disease; - Renal disease; - Malignancy | | | | | 1) Blood pressure: 12 week findings SBP (mmHg): Benazepril 128 ± 8 Valsartan 130 ± 9 DBP (mmHg): Benazepril 82 ± 7 Valsartan 80 ± 8 Blood pressure (SBP and DBP) was significantly reduced after 12-week antihypertensive therapy in all the three groups compared to their baseline blood pressure values (P < 0.05). There were no significant differences in the reduction of blood pressure between the groups. 2) Rate of use of a single antihypertensive agent for BP control: NR 3) Mortality: NR 4) Morbidity: NR 5) Safety: 2 benazepril patients withdrew because of cough 6) Specific adverse events: See immediately above 7) Persistence/adherence: 8 patients withdrew, 2 in the benazepril arm because of cough, 1 patient from the valsartan group because of failure of normalization of blood pressure, 4 patients due to failure to followup 8) Lipid levels: There were no significant changes in lipids compared to the baseline values (data not shown) 9) Progression to type 2 diabetes: NR 10) Markers of carbohydrate metabolism/diabetes control: There were no significant changes in glucose compared to the baseline values (data not shown) 11) LV mass/function: NR 12) Creatinine/GFR: There were no significant changes in serum BUN and creatinine concentrations at the end of antihypertensive therapy (P > 0.05). BUN (mg/dL): Benazepril (baseline/12 week) 16.0 ± 5.1/15.7 ± 5.3 Valsartan (baseline/12 week) 15.7 ± 4.8/16.0 ± 5.0 Creatinine (mg/dL): Benazepril (baseline/12 week) 1.04 ± 0.12/1.06 ± 0.15 Valsartan (baseline/12 week) 1.05 ± 0.11/1.04 ± 0.14 13) Proteinuria: ACR (mg/g): Benazepril (baseline/12 week) 332 ± 66/215 ± 54 Valsartan (baseline/12 week) 324 ± 57/211 ± 52 | | | | | | General comments: Main purpose of study was to explore relationship between transforming growth factor and kidney damage Quality assessment: Overall rating: Fair Comments:; - Incomplete followup; - Completers analysis; Applicability:; - Unclear how patients were chosen from original 156 patients in parent study

## Articles Included in the Evidence Table (Alphabetical Listing)

Akat PB, Bapat TR, Murthy MB, et al. Comparison of the efficacy and tolerability of telmisartan and enalapril in patients of mild to moderate essential hypertension. Indian Journal of Pharmacology. 2010;42(3):153-6. [pmid: 20871766].
Amerena J, Pappas S, Ouellet JP, et al. ABPM comparison of the anti-hypertensive profiles of telmisartan and enalapril in patients with mild-to-moderate essential hypertension. J Int Med Res. 2002;30(6):543-52. [pmid: 12526280].
Andersen K, Weinberger MH, Constance CM, et al. Comparative effects of aliskiren-based and ramipril-based therapy on the renin system during long-term (6 months) treatment and withdrawal in patients with hypertension. JRAAS - Journal of the Renin-Angiotensin-Aldosterone System. 2009;10(3):157-67.
Andersen K, Weinberger MH, Egan B, et al. Comparative efficacy and safety of aliskiren, an oral direct renin inhibitor, and ramipril in hypertension: a 6-month, randomized, double-blind trial. J Hypertens. 2008;26(3):589-99. [pmid: 18300872].
Andersen K, Weinberger MH, Egan B, et al. Comparative efficacy of aliskiren monotherapy and ramipril monotherapy in patients with stage 2 systolic hypertension: Subgroup analysis of a double-blind, active comparator trial. Cardiovascular Therapeutics. 2010;28(6):344-9. [pmid: 20406241].
Argenziano L, Trimarco B. Effect of eprosartan and enalapril in the treatment of elderly hypertensive patients: subgroup analysis of a 26-week, double-blind, multicentre study. Eprosartan Multinational Study Group. Curr Med Res Opin. 1999;15(1):9-14. [pmid: 10216806].
Avanza ACJ, El Aouar LM, Mill JG. Reduction in left ventricular hypertrophy in hypertensive patients treated with enalapril, losartan or the combination of enalapril and losartan. Arq Bras Cardiol. 2000;74(2):103-17. [pmid: 10904284].
Barnett AH, Bain SC, Bouter P, et al. Angiotensin-receptor blockade versus converting-enzyme inhibition in type 2 diabetes and nephropathy. erratum appears in N Engl J Med. 2005 Apr 21;352(16)1731. N Engl J Med. 2004;351(19):1952-61. [pmid: 15516696].
Black HR, Graff A, Shute D, et al. Valsartan, a new angiotensin II antagonist for the treatment of essential hypertension: efficacy, tolerability and safety compared to an angiotensin-converting enzyme inhibitor, lisinopril. J Hum Hypertens. 1997;11(8):483-9. [pmid: 9322828].
Bloom BS. Continuation of initial antihypertensive medication after 1 year of therapy. Clin Ther. 1998;20(4):671-81. [pmid: 9737827].
Bourgault C, Senecal M, Brisson M, et al. Persistence and discontinuation patterns of antihypertensive therapy among newly treated patients: a population-based study. J Hum Hypertens. 2005;19(8):607-13. [pmid: 15920457].
Breeze E, Rake EC, Donoghue MD, et al. Comparison of quality of life and cough on eprosartan and enalapril in people with moderate hypertension. J Hum Hypertens. 2001;15(12):857-62. [pmid: 11773988].
Burke TA, Sturkenboom MC, Lu SE, et al. Discontinuation of antihypertensive drugs among newly diagnosed hypertensive patients in UK general practice. J Hypertens. 2006;24(6):1193-200. [pmid: 16685222].
Celik T, Iyisoy A, Kursaklioglu H, et al. The comparative effects of telmisartan and ramipril on P-wave dispersion in hypertensive patients: a randomized clinical study. Clin Cardiol. 2005;28(6):298-302. [pmid: 16028466].
Coca A, Calvo C, Garcia-Puig J, et al. A multicenter, randomized, double-blind comparison of the efficacy and safety of irbesartan and enalapril in adults with mild to moderate essential hypertension, as assessed by ambulatory blood pressure monitoring: the MAPAVEL Study (Monitorizacion Ambulatoria Presion Arterial APROVEL). Clin Ther. 2002;24(1):126-38. [pmid: 11833827].
Conlin PR, Gerth WC, Fox J, et al. Four-year persistence patterns among patients initiating therapy with the angiotensin II receptor antagonist losartan versus other artihypertensive drug classes. Clin Ther. 2001;23(12):1999-2010. [pmid: 11813934].
Cotter J, Oliveira P, Cunha P, et al. Different patterns of one-year evolution of microalbuminuria in hypertensive patients treated with different inhibitors of the renin-angiotensin system. Rev Port Cardiol. 2008;27(11):1395-404. [pmid: 19227807].
Cuspidi C, Muiesan ML, Valagussa L, et al. Comparative effects of candesartan and enalapril on left ventricular hypertrophy in patients with essential hypertension: the candesartan assessment in the treatment of cardiac hypertrophy (CATCH) study. J Hypertens. 2002;20(11):2293-300. [pmid: 12409969].
De Rosa ML, Cardace P, Rossi M, et al. Comparative effects of chronic ACE inhibition and AT1 receptor blocked losartan on cardiac hypertrophy and renal function in hypertensive patients. J Hum Hypertens. 2002;16(2):133-40. [pmid: 11850771].
Degli Esposti E, Sturani A, Di Martino M, et al. Long-term persistence with antihypertensive drugs in new patients. J Hum Hypertens. 2002;16(6):439-44. [pmid: 12037702].
Degli Esposti L, Degli Esposti E, Valpiani G, et al. A retrospective, population-based analysis of persistence with antihypertensive drug therapy in primary care practice in Italy. Clin Ther. 2002;24(8):1347-57. discussion 6. [pmid: 12240784].
Delea TE, Taneja C, Moynahan A, et al. Valsartan versus lisinopril or extended-release metoprolol in preventing cardiovascular and renal events in patients with hypertension. Am J Health Syst Pharm. 2007;64(11):1187-96. [pmid: 17519461].
Derosa G, Cicero AF, Ciccarelli L, et al. A randomized, double-blind, controlled, parallel-group comparison of perindopril and candesartan in hypertensive patients with type 2 diabetes mellitus. Clin Ther. 2003;25(7):2006-21. [pmid: 12946547].
Deyneli O, Yavuz D, Velioglu A, et al. Effects of ACE inhibition and angiotension II receptor blockade on glomerular basement membrane protein excretion and change selectivity in type 2 diabetic patients. JRAAS - Journal of the Renin-Angiotensin-Aldosterone System. 2006;7(2):98-103.
Duprez DA, Munger MA, Botha J, et al. Aliskiren for geriatric lowering of systolic hypertension: A randomized controlled trial. J Hum Hypertens. 2010;24(9):600-8. Epub 2009 Dec 24. [pmid: 20033075].
Eguchi K, Kario K, Shimada K. Comparison of candesartan with lisinopril on ambulatory blood pressure and morning surge in patients with systemic hypertension. Am J Cardiol. 2003;92(5):621-4. [pmid: 12943892].
Elliott WJ. Double-blind comparison of eprosartan and enalapril on cough and blood pressure in unselected hypertensive patients. Eprosartan Study Group. J Hum Hypertens. 1999;13(6):413-7. [pmid: 10408592].
Erkens JA, Panneman MM, Klungel OH, et al. Differences in antihypertensive drug persistence associated with drug class and gender: a PHARMO study. Pharmacoepidemiology & Drug Safety. 2005;14(11):795-803. [pmid: 16178043].
Fernandez-Campo L, Grande MT, Diego J, et al. Effect of different antihypertensive treatments on Ras, MAPK and Akt activation in hypertension and diabetes. Clin Sci. 2009;116(2):165-73. [pmid: 18588512].
Fogari R, Derosa G, Ferrari I, et al. Effect of valsartan and ramipril on atrial fibrillation recurrence and P-wave dispersion in hypertensive patients with recurrent symptomatic lone atrial fibrillation. Am J Hypertens. 2008;21(9):1034-9. [pmid: 18566593].
Fogari R, Mugellini A, Zoppi A, et al. Losartan and perindopril effects on plasma plasminogen activator inhibitor-1 and fibrinogen in hypertensive type 2 diabetic patients. Am J Hypertens. 2002;15(4 Pt 1):316-20. [pmid: 11991216].
Fogari R, Mugellini A, Zoppi A, et al. Effect of telmisartan/hydrochlorothiazide vs lisinopril/hydrochlorothiazide combination on ambulatory blood pressure and cognitive function in elderly hypertensive patients. J Hum Hypertens. 2006;20(3):177-85. [pmid: 16306998].
Fogari R, Mugellini A, Zoppi A, et al. Effects of valsartan compared with enalapril on blood pressure and cognitive function in elderly patients with essential hypertension. Eur J Clin Pharmacol. 2004;59(12):863-8. [pmid: 14747881].
Fogari R, Zoppi A, Preti P, et al. Differential effects of ACE-inhibition and angiotensin II antagonism on fibrinolysis and insulin sensitivity in hypertensive postmenopausal women. Am J Hypertens. 2001;14(9 Pt 1):921-6. [pmid: 11587159].
Formosa V, Bellomo A, Iori A, et al. The treatment of hypertension with telmisartan in the sphere of circadian rhythm in metabolic syndrome in the elderly. Arch Gerontol Geriatr. 1. 2009;49:95-101. [pmid: 19836621].
Franke H. Antihypertensive effects of candesartan cilexetil, enalapril and placebo. J Hum Hypertens. 2. 1997;11:S61-2. [pmid: 9331010].
Gavras I, Gavras H. Effects of eprosartan versus enalapril in hypertensive patients on the renin-angiotensin-aldosterone system and safety parameters: results from a 26-week, double-blind, multicentre study. Eprosartan Multinational Study Group. Curr Med Res Opin. 1999;15(1):15-24. [pmid: 10216807].
Ghiadoni L, Magagna A, Versari D, et al. Different effect of antihypertensive drugs on conduit artery endothelial function. Hypertension. 2003;41(6):1281-6. [pmid: 12719441].
Gregoire JP, Moisan J, Guibert R, et al. Tolerability of antihypertensive drugs in a community-based setting. Clin Ther. 2001;23(5):715-26. [pmid: 11394730].
Guntekin U, Gunes Y, Tuncer M, et al. Comparison of the effects of quinapril and irbesartan on P-wave dispersion in hypertensive patients. Adv Ther. 2008;25(8):775-86. [pmid: 18670740].
Hasford J, Mimran A, Simons WR. A population-based European cohort study of persistence in newly diagnosed hypertensive patients. J Hum Hypertens. 2002;16(8):569-75. [pmid: 12149663].
Hasford J, Schroder-Bernhardi D, Rottenkolber M, et al. Persistence with antihypertensive treatments: results of a 3-year follow-up cohort study. Eur J Clin Pharmacol. 2007;63(11):1055-61. [pmid: 17701032].
Hermida RC, Ayala DE, Khder Y, et al. Ambulatory blood pressure-lowering effects of valsartan and enalapril after a missed dose in previously untreated patients with hypertension: a prospective, randomized, open-label, blinded end-point trial. Clin Ther. 2008;30(1):108-20. [pmid: 18343247].
Hosohata K, Saito S, Asayama K, et al. Progress report on The Hypertension Objective Treatment Based on Measurement by Electrical Devices of Blood Pressure (HOMED-BP) study: status at February 2004. Clinical & Experimental Hypertension (New York). 2007;29(1):69-81.
Karlberg BE, Lins LE, Hermansson K. Efficacy and safety of telmisartan, a selective AT1 receptor antagonist, compared with enalapril in elderly patients with primary hypertension. TEES Study Group. J Hypertens. 1999;17(2):293-302. [pmid: 10067800].
Kavgaci H, Sahin A, Onder Ersoz H, et al. The effects of losartan and fosinopril in hypertensive type 2 diabetic patients. Diabetes Res Clin Pract. 2002;58(1):19-25. [pmid: 12161053].
Kloner RA, Neutel J, Roth EM, et al. Blood pressure control with amlodipine add-on therapy in patients with hypertension and diabetes: results of the Amlodipine Diabetic Hypertension Efficacy Response Evaluation Trial. Ann Pharmacother. 2008;42(11):1552-62. [pmid: 18827176].
Koylan N, Acarturk E, Canberk A, et al. Effect of irbesartan monotherapy compared with ACE inhibitors and calcium-channel blockers on patient compliance in essential hypertension patients: a multicenter, open-labeled, three-armed study. Blood Pressure Supplement. 2005;1:23-31. [pmid: 16060413].
Lachaine J, Petrella RJ, Merikle E, et al. Choices, persistence and adherence to antihypertensive agents: evidence from RAMQ data. Can J Cardiol. 2008;24(4):269-73. [pmid: 18401466].
Lacourciere Y, Belanger A, Godin C, et al. Long-term comparison of losartan and enalapril on kidney function in hypertensive type 2 diabetics with early nephropathy. Kidney Int. 2000;58(2):762-9. [pmid: 10916100].
Lacourciere Y, Neutel JM, Davidai G, et al. A multicenter, 14-week study of telmisartan and ramipril in patients with mild-to-moderate hypertension using ambulatory blood pressure monitoring. Am J Hypertens. 2006;19(1):104-12. [pmid: 16461201].
Larochelle P, Flack JM, Marbury TC, et al. Effects and tolerability of irbesartan versus enalapril in patients with severe hypertension. Irbesartan Multicenter Investigators. Am J Cardiol. 1997;80(12):1613-5. [pmid: 9416950].
Levine B. Effect of eprosartan and enalapril in the treatment of black hypertensive patients: subgroup analysis of a 26-week, double-blind, multicentre study. Eprosartan Multinational Study Group. Curr Med Res Opin. 1999;15(1):25-32. [pmid: 10216808].
Mackay FJ, Pearce GL, Mann RD. Cough and angiotensin II receptor antagonists: cause or confounding?. Br J Clin Pharmacol. 1999;47(1):111-4. [pmid: 10073748].
Malacco E, Omboni S, Volpe M, et al. Antihypertensive efficacy and safety of olmesartan medoxomil and ramipril in elderly patients with mild to moderate essential hypertension: The ESPORT study. J Hypertens. 2010;28(11):2342-50. [pmid: 20829713].
Malacco E, Santonastaso M, Vari NA, et al. Comparison of valsartan 160 mg with lisinopril 20 mg, given as monotherapy or in combination with a diuretic, for the treatment of hypertension: the Blood Pressure Reduction and Tolerability of Valsartan in Comparison with Lisinopril (PREVAIL) study. erratum appears in Clin Ther. 2004 Jul;26(7):1185. Clin Ther. 2004;26(6):855-65. [pmid: 15262456].
Malde B, Regalado J, Greenberger PA. Investigation of angioedema associated with the use of angiotensin-converting enzyme inhibitors and angiotensin receptor blockers. Ann Allergy Asthma Immunol. 2007;98(1):57-63. [pmid: 17225721].
Mallion JM, Bradstreet DC, Makris L, et al. Antihypertensive efficacy and tolerability of once daily losartan potassium compared with captopril in patients with mild to moderate essential hypertension. Journal of Hypertension, Supplement. 1995;13(1):S35-S41.
Malmqvist K, Kahan T, Dahl M. Angiotensin II type 1 (AT1) receptor blockade in hypertensive women: benefits of candesartan cilexetil versus enalapril or hydrochlorothiazide. Am J Hypertens. 2000;13(5 Pt 1):504-11. [pmid: 10826401].
Marentette MA, Gerth WC, Billings DK, et al. Antihypertensive persistence and drug class. Can J Cardiol. 2002;18(6):649-56. [pmid: 12107422].
Matsuda H, Hayashi K, Saruta T. Distinct time courses of renal protective action of angiotensin receptor antagonists and ACE inhibitors in chronic renal disease. J Hum Hypertens. 2003;17(4):271-6. [pmid: 12692572].
Mazzaglia G, Mantovani LG, Sturkenboom MC, et al. Patterns of persistence with antihypertensive medications in newly diagnosed hypertensive patients in Italy: a retrospective cohort study in primary care. J Hypertens. 2005;23(11):2093-100. [pmid: 16208153].
McInnes GT, O'Kane KP, Istad H, et al. Comparison of the AT1-receptor blocker, candesartan cilexetil, and the ACE inhibitor, lisinopril, in fixed combination with low dose hydrochlorothiazide in hypertensive patients. J Hum Hypertens. 2000;14(4):263-9. [pmid: 10805052].
Menne J, Farsang C, Deak L, et al. Valsartan in combination with lisinopril versus the respective high dose monotherapies in hypertensive patients with microalbuminuria: the VALERIA trial. J Hypertens. 2008;26(9):1860-7. [pmid: 18698222].
Mimran A, Ruilope L, Kerwin L, et al. A randomised, double-blind comparison of the angiotensin II receptor antagonist, irbesartan, with the full dose range of enalapril for the treatment of mild-to-moderate hypertension. J Hum Hypertens. 1998;12(3):203-8. [pmid: 9579771].
Mogensen CE, Neldam S, Tikkanen I, et al. Randomised controlled trial of dual blockade of renin-angiotensin system in patients with hypertension, microalbuminuria, and non-insulin dependent diabetes: the candesartan and lisinopril microalbuminuria (CALM) study. BMJ. 2000;321(7274):1440-4. [pmid: 11110735].
Naidoo DP, Sareli P, Marin F, et al. Increased efficacy and tolerability with losartan plus hydrochlorothiazide in patients with uncontrolled hypertension and therapy-related symptoms receiving two monotherapies. Adv Ther. 1999;16(5):187-99. [pmid: 10915394].
Nakamura T, Kawachi K, Saito Y, et al. Effects of ARB or ACE-inhibitor administration on plasma levels of aldosterone and adiponectin in hypertension. International Heart Journal. 2009;50(4):501-12. [pmid: 19609054].
Neutel JM, Frishman WH, Oparil S, et al. Comparison of telmisartan with lisinopril in patients with mild-to-moderate hypertension. Am J Ther. 1999;6(3):161-6. [pmid: 10423659].
Nielsen S, Dollerup J, Nielsen B, et al. Losartan reduces albuminuria in patients with essential hypertension. An enalapril controlled 3 months study. Nephrology Dialysis Transplantation. 2. 1997;12:19-23.
Onal IK, Altun B, Onal ED, et al. Serum levels of MMP-9 and TIMP-1 in primary hypertension and effect of antihypertensive treatment. European Journal of Internal Medicine. 2009;20(4):369-72. [pmid: 19524176].
Ozturk S, Sar F, Bengi-Bozkurt O, et al. Study of ACEI versus ARB in managing hypertensive overt diabetic nephropathy: long-term analysis. Kidney & Blood Pressure Research. 2009;32(4):268-75. [pmid: 19776644].
Patel BV, Remigio-Baker RA, Mehta D, et al. Effects of initial antihypertensive drug class on patient persistence and compliance in a usual-care setting in the United States. J Clin Hypertens. 2007;9(9):692-700.
Rabbia F, Silke B, Carra R, et al. Heart rate variability and baroreflex sensitivity during fosinopril, irbesartan and atenolol therapy in hypertension. Clinical Drug Investigation. 2004;24(11):651-9. [pmid: 17523728].
Ragot S, Ezzaher A, Meunier A, et al. Comparison of trough effect of telmisartan vs perindopril using self blood pressure measurement: EVERESTE study. J Hum Hypertens. 2002;16(12):865-73. [pmid: 12522468].
Rajzer M, Klocek M, Kawecka-Jaszcz K. Effect of amlodipine, quinapril, and losartan on pulse wave velocity and plasma collagen markers in patients with mild-to-moderate arterial hypertension. Am J Hypertens. 2003;16(6):439-44. [pmid: 12799091].
Rehman A, Ismail SB, Naing L, et al. Reduction in arterial stiffness with angiotensin II antagonism and converting enzyme inhibition. A comparative study among malay hypertensive subjects with a known genetic profile. Am J Hypertens. 2007;20(2):184-9. [pmid: 17261465].
Robles NR, Angulo E, Grois J, et al. Comparative effects of fosinopril and irbesartan on hematopoiesis in essential hypertensives. Ren Fail. 2004;26(4):399-404. [pmid: 15462108].
Roca-Cusachs A, Oigman W, Lepe L, et al. A randomized, double-blind comparison of the antihypertensive efficacy and safety of once-daily losartan compared to twice-daily captopril in mild to moderate essential hypertension. Acta Cardiol. 1997;52(6):495-506. [pmid: 9542575].
Rosei EA, Rizzoni D, Muiesan ML, et al. Effects of candesartan cilexetil and enalapril on inflammatory markers of atherosclerosis in hypertensive patients with non-insulin-dependent diabetes mellitus. J Hypertens. 2005;23(2):435-44. [pmid: 15662233].
Ruff D, Gazdick LP, Berman R, et al. Comparative effects of combination drug therapy regimens commencing with either losartan potassium, an angiotensin II receptor antagonist, or enalapril maleate for the treatment of severe hypertension. J Hypertens. 1996;14(2):263-70. [pmid: 8728306].
Ruilope L, Jager B, Prichard B. Eprosartan versus enalapril in elderly patients with hypertension: a double-blind, randomized trial. Blood Press. 2001;10(4):223-9. [pmid: 11800061].
Saito S, Asayama K, Ohkubo T, et al. The second progress report on the Hypertension Objective treatment based on Measurement by Electrical Devices of Blood Pressure (HOMED-BP) study. Blood Press Monit. 2004;9(5):243-7. [pmid: 15472496].
Sanchez RA, Masnatta LD, Pesiney C, et al. Telmisartan improves insulin resistance in high renin nonmodulating salt-sensitive hypertensives. J Hypertens. 2008;26(12):2393-8. [pmid: 19008718].
Sato A, Tabata M, Hayashi K, et al. Effects of the angiotensin II type 1 receptor antagonist candesartan, compared with angiotensin-converting enzyme inhibitors, on the urinary excretion of albumin and type IV collagen in patients with diabetic nephropathy. Clinical & Experimental Nephrology. 2003;7(3):215-20. [pmid: 14586718].
Scaglione R, Argano C, Di Chiara T, et al. Effect of dual blockade of renin-angiotensin system on TGFbeta1 and left ventricular structure and function in hypertensive patients. J Hum Hypertens. 2007;21(4):307-15. [pmid: 17301824].
Schieffer B, Bunte C, Witte J, et al. Comparative effects of AT1-antagonism and angiotensin-converting enzyme inhibition on markers of inflammation and platelet aggregation in patients with coronary artery disease. J Am Coll Cardiol. 2004;44(2):362-8. [pmid: 15261932].
Schram MT, van Ittersum FJ, Spoelstra-de Man A, et al. Aggressive antihypertensive therapy based on hydrochlorothiazide, candesartan or lisinopril as initial choice in hypertensive type II diabetic individuals: effects on albumin excretion, endothelial function and inflammation in a double-blind, randomized clinical trial. J Hum Hypertens. 2005;19(6):429-37. [pmid: 15647778].
Sengul AM, Altuntas Y, Kurklu A, et al. Beneficial effect of lisinopril plus telmisartan in patients with type 2 diabetes, microalbuminuria and hypertension. Diabetes Res Clin Pract. 2006;71(2):210-9. [pmid: 16112244].
Shand BI. Haemorheological effects of losartan and enalapril in patients with renal parenchymal disease and hypertension. J Hum Hypertens. 2000;14(5):305-9. [pmid: 10822316].
Shand BI, Lynn KL. A comparative study of losartan and enalapril on erythropoiesis and renal function in hypertensive patients with renal parenchymal disease. Clin Nephrol. 2000;54(5):427-8. [pmid: 11105808].
Shibasaki Y, Masaki H, Nishiue T, et al. Angiotensin II type 1 receptor antagonist, losartan, causes regression of left ventricular hypertrophy in end-stage renal disease. Nephron. 2002;90(3):256-61. [pmid: 11867945].
Simons LA, Ortiz M, Calcino G. Persistence with antihypertensive medication: Australia-wide experience, 2004-2006. Med J Aust. 2008;188(4):224-7. [pmid: 18279129].
Solomon SD, Appelbaum E, Manning WJ, et al. Effect of the direct Renin inhibitor aliskiren, the Angiotensin receptor blocker losartan, or both on left ventricular mass in patients with hypertension and left ventricular hypertrophy. Circulation. 2009;119(4):530-7. [pmid: 19153265].
Sonoda M, Aoyagi T, Takenaka K, et al. A one-year study of the antiatherosclerotic effect of the angiotensin-II receptor blocker losartan in hypertensive patients. A comparison with angiotension-converting enzyme inhibitors. International Heart Journal. 2008;49(1):95-103. [pmid: 18360068].
Souza-Barbosa LA, Ferreira-Melo SE, Ubaid-Girioli S, et al. Endothelial vascular function in hypertensive patients after renin-angiotensin system blockade. J Clin Hypertens. 2006;8(11):803-9. quiz 10-1.
Spinar J, Vitovec J, Soucek M, et al. CORD: COmparsion of Recommended Doses of ACE inhibitors and angiotensin II receptor blockers. Vnitrni Lekarstvi. 2009;55(5):481-8. [pmid: 19514614].
Spoelstra-de Man AM, van Ittersum FJ, Schram MT, et al. Aggressive antihypertensive strategies based on hydrochlorothiazide, candesartan or lisinopril decrease left ventricular mass and improve arterial compliance in patients with type II diabetes mellitus and hypertension. J Hum Hypertens. 2006;20(8):599-611. [pmid: 16673014].
Tedesco MA, Natale F, Calabro R. Effects of monotherapy and combination therapy on blood pressure control and target organ damage: a randomized prospective intervention study in a large population of hypertensive patients. J Clin Hypertens. 2006;8(9):634-41.
Tikkanen I, Omvik P, Jensen HA. Comparison of the angiotensin II antagonist losartan with the angiotensin converting enzyme inhibitor enalapril in patients with essential hypertension. J Hypertens. 1995;13(11):1343-51. [pmid: 8984133].
Townsend R, Haggert B, Liss C, et al. Efficacy and tolerability of losartan versus enalapril alone or in combination with hydrochlorothiazide in patients with essential hypertension. Clin Ther. 1995;17(5):911-23. [pmid: 8595643].
Uchiyama-Tanaka Y, Mori Y, Kishimoto N, et al. Comparison of the effects of quinapril and losartan on carotid artery intima-media thickness in patients with mild-to-moderate arterial hypertension. Kidney & Blood Pressure Research. 2005;28(2):111-6. [pmid: 15741734].
Verdecchia P, Schillaci G, Reboldi GP, et al. Long-term effects of losartan and enalapril, alone or with a diuretic, on ambulatory blood pressure and cardiac performance in hypertension: a case-control study. Blood Press Monit. 2000;5(3):187-93. [pmid: 10915233].
Veronesi M, Cicero AF, Prandin MG, et al. A prospective evaluation of persistence on antihypertensive treatment with different antihypertensive drugs in clinical practice. Vascular Health & Risk Management. 2007;3(6):999-1005. [pmid: 18200818].
Williams B, Gosse P, Lowe L, et al. The prospective, randomized investigation of the safety and efficacy of telmisartan versus ramipril using ambulatory blood pressure monitoring (PRISMA I). J Hypertens. 2006;24(1):193-200. [pmid: 16331118].
Wogen J, Kreilick CA, Livornese RC, et al. Patient adherence with amlodipine, lisinopril, or valsartan therapy in a usual-care setting. Journal of Managed Care Pharmacy. 2003;9(5):424-9. [pmid: 14613440].
Xu D, Liu J, Ji C, et al. Effects of telmisartan on hypertensive patients with dyslipidemia and insulin resistance. Journal of Geriatric Cardiology. 2007;4(3):149-52.
Yilmaz MI, Sonmez A, Caglar K, et al. Effect of antihypertensive agents on plasma adiponectin levels in hypertensive patients with metabolic syndrome. Nephrology. 2007;12(2):147-53. [pmid: 17371337].
Yokoyama K, Yang W, Preblick R, et al. Effects of a step-therapy program for angiotensin receptor blockers on antihypertensive medication utilization patterns and cost of drug therapy. see comment. Journal of Managed Care Pharmacy. 2007;13(3):235-44. [pmid: 17407390].
Zhu S, Liu Y, Wang L, et al. Transforming growth factor-(beta)(1) is associated with kidney damage in patients with essential hypertension: Renoprotective effect of ACE inhibitor and/or angiotensin II receptor blocker. Nephrology Dialysis Transplantation. 2008;23(9):2841-6.