# Data Abstraction Form

Study | Interventions and study design | Patient characteristics | Results | Comments/quality/applicability
StudyID | Geographical location: [city & state (U.S.) or city & country (foreign)] Study dates: [month & year] Funding source: Interventions: [For each treatment arm, describe drug, dose (incl. titration protocol), and number of patients randomized] Were additional anti-hypertension medications allowed: [Delete all but one] Yes/No/NR = not reported If Yes to above, was this done: [delete all but one] Per protocol At discretion of clinician/investigator NR Study design: [Delete all but one] RCT, parallel-group RCT, crossover Other [specify] Blinding: [For each item, Yes/No/NR]; - Patients:; - Providers:; - Assessors of outcomes:; Was allocation concealment adequate? [e.g., computer-generated list or central randomization] Yes/No/NR Baseline/run-in period: [length & intervention, or NA = not applicable] Washout period(s): [crossover trials only; length] Duration of treatment: [post-baseline/run-in; days, weeks, months] Duration of post-treatment followup: [days, weeks, months, or NA = not applicable] | Number of patients:; - Screened for inclusion:; - Eligible for inclusion:; - Randomized:; - Began treatment:; - Completed treatment:; - Withdrawals/losses to followup:; Age: Mean (SD): Median: Range: Sex (n [%]): Female: Male: Race/ethnicity (n [%]): Baseline blood pressure: [by treatment group, if given; indicate how assessed] Concurrent non-hypertension medications (n [%]): Comorbidities (n [%]): Recruitment setting: [Inclusion/exclusion criteria: describe these as reported in article. If tolerability was assessed during run-in or used as an incl/excl criterion, please note this.] Inclusion criteria: Exclusion criteria: | [Where necessary, specify how outcomes were defined and assessed. Report quantitative data and p-values, where available; give N's for specific outcomes if these differ from N's randomized; give time point(s) for abstracted data and note other time points available in the article. Include any results reported separately for subgroups of patients based on demographic characteristics (age, racial and ethnic groups, sex), use of other medications concurrently, or co-morbidities.] 1) Blood pressure: [Prefer seated trough BP, if reported; if BP outcomes other than the one(s) you abstract are reported, list these] 2) Rate of use of a single antihypertensive agent for BP control: 3) Mortality: [all-cause, cardiovascular disease-specific, and cerebrovascular disease-specific] 4) Morbidity: [cardiac events (MI), heart failure, cerebral vascular disease or events (incl. stroke), symptomatic coronary artery disease, end-stage renal disease, PVD, quality of life] 5) Safety: [overall adverse events (AEs), withdrawals due to AEs, serious AEs reported, switch rates] 6) Specific adverse events: [including, but not limited to: weight gain, impaired renal function, hyperkalemia, angioedema, cough]: 7) Persistence/adherence: 8) Lipid levels: 9) Progression to type 2 diabetes: 10) Markers of carbohydrate metabolism/diabetes control: [HbA1c, insulin or other diabetes med dosage, fasting plasma glucose, aggregated measures of serial glucose measurements] 11) LV mass/function: 12) Creatinine/GFR: 13) Proteinuria: | [IF ARTICLE SHOULD BE EXCLUDED, PLEASE EXPLAIN WHY HERE] General comments: [Comment here on biases, etc., affecting clinical interpretation] Quality assessment: [Assign an overall quality rating of “Good,” “Fair,” or “Poor” based on the definitions provided in the guidance sheet. If study is rated as “Fair” or “Poor,” note important limitations in internal validity (see guidance sheet assessing quality) under “Comments”, below.] Overall rating: Comments: Applicability: [List the most important (up to 3) limitations affecting applicability, if any, based on the list given in the guidance sheet on assessing applicability.] This article is relevant to: [Delete as appropriate] Question 1 Question 2 Question 3