# Abstract and Full-Text Screening Criteria

## Abstract Screening Criteria

An abstract will be [underlined: included] if all of the following criteria apply:

- The study is a [underlined: direct comparison] (any study design) of an angiotensin-converting enzyme inhibitor (ACEI) versus an angiotensin II receptor antagonist (ARB), or an ACEI versus a renin inhibitor, or an ARB versus a renin inhibitor (see lists at end of this document for included drugs; additional antihypertensive therapy OK if the same in both groups);
- Original data.

An abstract will be [underlined: excluded] if any of the following criteria apply:

- No patients have hypertension OR some patients have hypertension, but results not reported separately for this subgroup;
- All subjects aged < 18 years OR some subjects aged < 18 years, but results not broken down by age;
- Only comparison is an ACEI + an ARB versus placebo.

An abstract will be identified as a [underlined: review] if it is a relevant review article, meta-analysis, methods article, or cost-effectiveness analysis.

For each abstract, please mark either “EX” for [underlined: Exclude], “IN” for [underlined: Include] or “Rev” for [underlined: Review].

For included studies, please mark:

- “AcVAr” if the study is a [underlined: direct comparison] of an ACEI versus an ARB;
- “AcVR” if the study is a [underlined: direct comparison] of an ACEI versus a direct renin inhibitor
- “ArVR” if the study is a [underlined: direct comparison] of an ARB versus a direct renin inhibitor

For all included studies, please also indicate the [underlined: longest length (weeks or months) of followup].

Thus, coding for each abstract should be either:

- EX
- Rev
- IN AcVAr (specify # weeks or # months followup, or write “NS” if length of followup not specified)
- IN AcVR (specify # weeks or # months followup, or write “NS” if length of followup not specified)
- IN ArVR (specify # weeks or # months followup, or write “NS” if length of followup not specified)
- Info (if full-text needed to assess eligibility)

## Full-Text Screening Criteria

Note: Screeners were instructed to work from top to bottom of the following list, choosing the first (if any) exclusion reason that applied.

1. Condition of interest = essential hypertension
  ◦ Exclude if no patients have essential hypertension or if results not reported separately for subgroup with essential hypertension
2. Population of interest = adults (≥ 18 years)
  ◦ Exclude if all subjects < 18 or if results not reported separately for ≥ 18 subgroup
3. Interventions & comparators of interest:
  [underlined: ACEIs, ARBs, and direct renin inhibitors listed at end of this document]
  ◦ Include “grouped” comparisons, e.g., specific ARB vs. “ACE inhibitors” or unspecified “ARBs” vs. unspecified “ACEIs”
  ◦ Include ACEI + drug X vs. ARB + drug X (e.g., losartan + HCTZ vs. enalapril + HCTZ)
  ◦ Exclude ACEI + drug X vs. ARB + drug Y (e.g., enalapril + manidipine vs. irbesartan + HCTZ)
  ◦ Exclude if ACEI, ARB, or direct renin inhibitor not on lists at end of this document
4. Study designs:
  ◦ Include all clinical study designs (RCTs, non-RCTs, cohorts, etc.); cross-sectional studies OK if time on treatment reported and ≥ 12 weeks
  ◦ Exclude if not clinical study (review, etc. – please specify)
5. Outcomes of interest:
  For Key Question 1 and 3:
  ◦ Intermediate outcomes:
    ▪ Blood pressure control
    ▪ Rate of use of a single antihypertensive agent for blood pressure control
    ▪ Lipid levels
    ▪ Progression to type 2 diabetes
    ▪ Markers of carbohydrate metabolism/diabetes control (glycated hemoglobin [HbA1c], dosage of insulin or other diabetes medication, fasting plasma glucose, aggregated measures of serial glucose measurements)
    ▪ LV mass/function
    ▪ Creatinine/GFR
    ▪ Proteinuria
  ◦ Health outcomes:
    ▪ Mortality (all-cause, cardiovascular disease-specific, and cerebrovascular disease-specific)
    ▪ Morbidity (cardiac events (myocardial infarction, heart failure, cerebral vascular disease or events [including stroke], symptomatic coronary artery disease, end-stage renal disease, PVD [as clinically manifest, not markers of], quality of life)
    For Key Question 2 and 3:
    ◦ Safety (overall adverse events, withdrawals due to adverse events, serious adverse events reported, withdrawal rates, switch rates)
    ◦ Specific adverse events (including, but not limited to: weight gain, impaired renal function, angioedema, cough, hyperkalemia)
    ◦ Tolerability
    - Persistence
    ◦ Adherence
  - Sample size:
    ◦ We will not exclude articles based on sample size during the full text screening but may re-visit this decision when performing the full-text abstraction and synthesis.
  - Treatment duration/length of followup:
    ◦ Exclude if treatment duration or longest followup < 12 weeks
  [underlined: Included ACEIs]
  - Benazepril (Lotensin)
  - Captopril (Capoten)
  - Enalapril/Enalaprilat (Vasotec; Enalaprilat IV)
  - Fosinopril (Monopril)
  - Lisinopril (Prinivil, Zestril)
  - Moexipril (Univasc)
  - Perindopril (Aceon)
  - Quinapril (Accupril)
  - Ramipril (Altace)
  - Trandolapril (Mavik)
  [underlined: Included ARBs]
  - Candesartan cilexetil (Atacand)
  - Eprosartan (Teveten)
  - Irbesartan (Avapro)
  - Losartan (Cozaar)
  - Olmesartan medoxomil (Benicar)
  - Telmisartan (Micardis)
  - Valsartan (Diovan)
  [underlined: Included direct renin inhibitor]
  - Aliskiren (Tekturna)