# Methods for Reviewing Indirect Comparison Studies

## Introduction

Our original 2007 review of the literature on the comparative long-term benefits and harms of angiotensin-converting enzyme inhibitors (ACEIs) versus angiotensin II receptor antagonists (ARBs) for treating hypertension focused, in the first instance, on direct head-to-head comparisons of drugs in the two classes. In that report, because we were uncertain that these direct comparisons would adequately address all aspects of the key questions, we also sought to identify and screen potentially relevant indirect comparison studies—that is, studies in which ACEIs and ARBs were compared, in distinct trials, with a common comparator. This appendix describes the methods we used to identify and review indirect comparison studies as part of the original report. Given the findings of that analysis—and subsequent decision to restrict our updated report to direct head-to-head comparisons—we did not repeat this analysis using the updated evidence base.

## Search and Abstract Screening

We began by searching MEDLINE for studies of ARBs versus other (non-ACEI) comparators, including placebo (see MEDLINE Search 1 in Appendix A). We screened these abstracts along with the head-to-head trials (see the abstract screening criteria in Appendix C). Note that, for indirect comparisons, we considered only randomized controlled trials (RCTs). We coded each included abstract for treatment duration/length of followup (“12 weeks”, “1 year”, etc.).

Because a primary objective for evaluating non-head-to-head studies was to expand the pool of evidence regarding long-term results, we restricted the pool of abstracts for further evaluation to those with a treatment duration/length of followup of ≥ 24 weeks. Further, since the credibility of any meta-analysis – particularly for non-head-to-head trials – depends on consistency among studies, we considered only comparators for which there were ≥ 3 trials. The comparators thus identified were atenolol, amlodipine, and placebo.

Next, we searched MEDLINE for studies of ACEIs versus atenolol or amlodipine (see MEDLINE Search 2 in Appendix A). To identify potentially relevant ACEI-versus-placebo trials, we began by searching the references of the June 2005 Drug Class Review on Angiotensin Converting Enzyme Inhibitors^*^ and supplemented this with a search of MEDLINE for articles published after that review (see MEDLINE Search 3 in Appendix A). Finally, the abstracts for all ACEI-versus-other studies were screened for inclusion and evaluated further to identify trials with the right treatment duration/length of followup (≥ 24 weeks) and the right comparators (atenolol, amlodipine, or placebo).

* Chou R, Helfand M, Carson S. Drug Class Review on Angiotensin Converting Enzyme Inhibitors. Final Report. June 2005. Available at: www.ohsu.edu/drugeffectiveness/reports/final.cfm. Accessed 17 August 2006.

The result of this process was that we identified 76 RCT publications comparing ARBs with atenolol, amlodipine, or placebo over a period of ≥ 24 weeks, and 136 RCT publications comparing ACEIs with the same group of comparators over the same period of time. We were unable to obtain copies of 4 articles (2 each for ACEIs and ARBs), so the final counts were 74 potentially relevant ARB articles and 134 potentially relevant ACEI articles.

## Identifying Publications Reporting Outcomes of Interest

Once data from the direct comparator trials had been abstracted, we identified three categories of outcomes that we thought were under-reported in these trials:

- Mortality and major events (myocardial infarction [MI], stroke);
- Measures of carbohydrate metabolism/diabetes control (progression to type 2 diabetes, glycated hemoglobin [HgbA1c], insulin or other diabetes medication dosage, fasting plasma glucose, or aggregated measures of serial glucose measurements);
- Measures of kidney disease (creatinine/glomerular filtration rate [GFR] and proteinuria).

We then screened the indirect comparison literature identified through the process described above in full-text form to identify publications that reported on one or more of these outcomes. Thirty-two (32) ARB-versus-other publications and 42 ACEI-versus-other publications reported one or more of the outcomes of interest and were evaluated further. A list of these 74 publications is provided at the end of this Appendix.

## Analysis of Comparability of Trials

In consideration of the special challenges of using indirect (non-head-to-head) comparison studies to infer relative efficacy regarding any particular health outcome, we established minimal criteria before considering any indirect comparison. Our goal was to achieve a reasonable degree of clinical homogeneity without being excessively restrictive at this stage.

We defined three criteria for considering performing an indirect comparison. The first criterion was that the studies must have a common comparator (amlodipine, atenolol, or placebo). The rationale is that comparators cannot be considered equivalent with regard to any particular health outcome. The second criterion was that study populations must be generally comparable, at least with regard to key characteristics relevant to the outcome being assessed. For studies examining event rates (mortality, stroke, or MI), the key characteristic was the mean age of the population. For studies of laboratory measures (HgbA1c, glucose, creatinine, GFR, or proteinuria), the key characteristic was the mean of the corresponding laboratory measure at baseline. The value for the key characteristic could be different by as much as 10 percent and still be considered to be comparable (e.g., for mortality rates in which the study with the highest mean age for subjects was 70 years, comparable studies could have mean subject ages as low as 63 years). The third criterion was that among studies satisfying the preceding criteria, there must be more than one study of an ACEI versus the comparator and more than one study of an ARB versus the comparator. That is, indirect comparisons for a particular outcome would be considered only if there were at least four comparable studies to evaluate, two for an ACEI and two for an ARB. Notably, we did not restrict studies to the same ACEI or ARB, or any other protocol characteristics.

Despite these relatively liberal criteria for considering indirect comparisons between ACEIs and ARBs, we did not identify any appropriate candidate studies related to an outcome of special interest, and thus we did not attempt to use indirect evidence to infer relative impact of ACEIs versus ARBs.

## List of Indirect Comparator Articles Reaching the Final Stage of Evaluation

The following is a list of the 74 indirect comparator publications from our original report that met our basic screening criteria (RCT, followup ≥ 24 weeks, comparator with ≥ 3 trials on ACEI and ARB sides) and reported one or more of the outcomes of interest specified above (mortality, MI, stroke, diabetes outcomes, kidney disease outcomes).

Aberg H, Morlin C, Lithell H. Different long-term metabolic effects of enalapril and atenolol in patients with mild hypertension. EGTA Group. J Hum Hypertens. 1995;9(2):149-53. [pmid: 7752178].
Agodoa LY, Appel L, Bakris GL, et al. Effect of ramipril vs amlodipine on renal outcomes in hypertensive nephrosclerosis: a randomized controlled trial. JAMA. 2001;285(21):2719-28. [pmid: 11386927].
ALLHAT Officers and Coordinators for the ALLHAT Collaborative Research Group, The Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial. Major outcomes in high-risk hypertensive patients randomized to angiotensin-converting enzyme inhibitor or calcium channel blocker vs diuretic: The Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). erratum appears in JAMA 2003 Jan 8;289(2):178. JAMA. 2002;288(23):2981-97. [pmid: 12479763].
Anonymous. The treatment of mild hypertension study. A randomized, placebo-controlled trial of a nutritional-hygienic regimen along with various drug monotherapies. The Treatment of Mild Hypertension Research Group. Arch Intern Med. 1991;151(7):1413-23. [pmid: 2064494].
Anonymous. Hypertension in Diabetes Study. III. Prospective study of therapy of hypertension in type 2 diabetic patients: efficacy of ACE inhibition and beta-blockade. Diabet Med. 1994;11(8):773-82. [pmid: 7851072].
Anonymous. Hypertension in Diabetes Study IV. Therapeutic requirements to maintain tight blood pressure control. erratum appears in Diabetologia 1997 Mar;40(3):366. Diabetologia. 1996;39(12):1554-61. [pmid: 8960842].
Anonymous. Efficacy of atenolol and captopril in reducing risk of macrovascular and microvascular complications in type 2 diabetes: UKPDS 39. UK Prospective Diabetes Study Group. BMJ. 1998;317(7160):713-20. [pmid: 9732338].
Anonymous. Tight blood pressure control and risk of macrovascular and microvascular complications in type 2 diabetes: UKPDS 38. UK Prospective Diabetes Study Group. erratum appears in BMJ 1999 Jan 2;318(7175):29. BMJ. 1998;317(7160):703-13. [pmid: 9732337].
Arima H, Hart RG, Colman S, et al. Perindopril-based blood pressure-lowering reduces major vascular events in patients with atrial fibrillation and prior stroke or transient ischemic attack. Stroke. 2005;36(10):2164-9. [pmid: 16141420].
Bakris GL, Weir MR, Shanifar S, et al. Effects of blood pressure level on progression of diabetic nephropathy: results from the RENAAL study. Arch Intern Med. 2003;163(13):1555-65. [pmid: 12860578].
Berl T, Hunsicker LG, Lewis JB, et al. Cardiovascular outcomes in the Irbesartan Diabetic Nephropathy Trial of patients with type 2 diabetes and overt nephropathy. summary for patients in Ann Intern Med. 2003 Apr 1;138(7):I43; PMID: 12667050. Ann Intern Med. 2003;138(7):542-9. [pmid: 12667024].
Brenner BM, Cooper ME, de Zeeuw D, et al. Effects of losartan on renal and cardiovascular outcomes in patients with type 2 diabetes and nephropathy. N Engl J Med. 2001;345(12):861-9. [pmid: 11565518].
Carr AA, Kowey PR, Devereux RB, et al. Hospitalizations for new heart failure among subjects with diabetes mellitus in the RENAAL and LIFE studies. Am J Cardiol. 2005;96(11):1530-6. [pmid: 16310435].
Chapman N, Huxley R, Anderson C, et al. Effects of a perindopril-based blood pressure-lowering regimen on the risk of recurrent stroke according to stroke subtype and medical history: the PROGRESS Trial. Stroke. 2004;35(1):116-21. [pmid: 14671247].
Cocco G, Ettlin T, Baumeler HR. The effect of amlodipine and enalapril on blood pressure and neurohumoral activation in hypertensive patients with Ribbing's disease (multiple epiphysal dystrophy). Clin Cardiol. 2000;23(2):109-14. [pmid: 10676602].
Contreras G, Greene T, Agodoa LY, et al. Blood pressure control, drug therapy, and kidney disease. Hypertension. 2005;46(1):44-50. [pmid: 15897360].
Dahlof B, Devereux RB, Kjeldsen SE, et al. Cardiovascular morbidity and mortality in the Losartan Intervention For Endpoint reduction in hypertension study (LIFE): a randomised trial against atenolol. Lancet. 2002;359(9311):995-1003. [pmid: 11937178].
Davis BR, Piller LB, Cutler JA, et al. Role of diuretics in the prevention of heart failure: the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial. Circulation. 2006;113(18):2201-10. [pmid: 16651474].
De Cesaris R, Ranieri G, Filitti V, et al. Effects of atenolol and enalapril on kidney function in hypertensive diabetic patients. J Cardiovasc Pharmacol. 1993;22(2):208-14. [pmid: 7692159].
Derosa G, Ragonesi PD, Mugellini A, et al. Effects of telmisartan compared with eprosartan on blood pressure control, glucose metabolism and lipid profile in hypertensive, type 2 diabetic patients: a randomized, double-blind, placebo-controlled 12-month study. Hypertens Res. 2004;27(7):457-64. [pmid: 15302981].
Devereux RB, Dahlof B, Kjeldsen SE, et al. Effects of losartan or atenolol in hypertensive patients without clinically evident vascular disease: a substudy of the LIFE randomized trial. Ann Intern Med. 2003;139(3):169-77. [pmid: 12899584].
Douglas JG, Agodoa L. ACE inhibition is effective and renoprotective in hypertensive nephrosclerosis: the African American Study of Kidney Disease and Hypertension (AASK) trial. Kidney Int Suppl. 2003;(83):S74-6. [pmid: 12864879].
Ecder T, Chapman AB, Brosnahan GM, et al. Effect of antihypertensive therapy on renal function and urinary albumin excretion in hypertensive patients with autosomal dominant polycystic kidney disease. Am J Kidney Dis. 2000;35(3):427-32. [pmid: 10692268].
Fogari R, Preti P, Zoppi A, et al. Effects of amlodipine fosinopril combination on microalbuminuria in hypertensive type 2 diabetic patients. Am J Hypertens. 2002;15(12):1042-9. [pmid: 12460699].
Fossum E, Moan A, Kjeldsen SE, et al. The effect of losartan versus atenolol on cardiovascular morbidity and mortality in patients with hypertension taking aspirin: the Losartan Intervention for Endpoint Reduction in hypertension (LIFE) study. J Am Coll Cardiol. 2005;46(5):770-5. [pmid: 16139123].
Gray A, Clarke P, Raikou M, et al. An economic evaluation of atenolol vs. captopril in patients with Type 2 diabetes (UKPDS 54). Diabet Med. 2001;18(6):438-44. [pmid: 11472461].
Hansson L. Effects of angiotensin-converting enzyme inhibition versus conventional antihypertensive therapy on the glomerular filtration rate. Cardiology. 1. 1995;86:30-3. [pmid: 7614504].
Hansson L, Lindholm LH, Ekbom T, et al. Randomised trial of old and new antihypertensive drugs in elderly patients: cardiovascular mortality and morbidity the Swedish Trial in Old Patients with Hypertension-2 study. Lancet. 1999;354(9192):1751-6. [pmid: 10577635].
Himmelmann A, Hansson L, Hansson BG, et al. ACE inhibition preserves renal function better than beta-blockade in the treatment of essential hypertension. Blood Press. 1995;4(2):85-90. [pmid: 7599759].
Himmelmann A, Hansson L, Hansson BG, et al. Long-term renal preservation in essential hypertension. Angiotensin converting enzyme inhibition is superior to beta-blockade. Am J Hypertens. 1996;9(9):850-3. [pmid: 8879340].
Hoieggen A, Alderman MH, Kjeldsen SE, et al. The impact of serum uric acid on cardiovascular outcomes in the LIFE study. Kidney Int. 2004;65(3):1041-9. [pmid: 14871425].
Ibsen H, Wachtell K, Olsen MH, et al. Does albuminuria predict cardiovascular outcome on treatment with losartan versus atenolol in hypertension with left ventricular hypertrophy? A LIFE substudy. J Hypertens. 2004;22(9):1805-11. [pmid: 15311110].
Iino Y, Hayashi M, Kawamura T, et al. Interim evidence of the renoprotective effect of the angiotensin II receptor antagonist losartan versus the calcium channel blocker amlodipine in patients with chronic kidney disease and hypertension: a report of the Japanese Losartan Therapy Intended for Global Renal Protection in Hypertensive Patients (JLIGHT) Study. Clin Exp Nephrol. 2003;7(3):221-30. [pmid: 14586719].
Iino Y, Hayashi M, Kawamura T, et al. Renoprotective effect of losartan in comparison to amlodipine in patients with chronic kidney disease and hypertension--a report of the Japanese Losartan Therapy Intended for the Global Renal Protection in Hypertensive Patients (JLIGHT) study. Hypertens Res. 2004;27(1):21-30. [pmid: 15055252].
Julius S, Alderman MH, Beevers G, et al. Cardiovascular risk reduction in hypertensive black patients with left ventricular hypertrophy: the LIFE study. J Am Coll Cardiol. 2004;43(6):1047-55. [pmid: 15028365].
Julius S, Kjeldsen SE, Weber M, et al. Outcomes in hypertensive patients at high cardiovascular risk treated with regimens based on valsartan or amlodipine: the VALUE randomised trial. Lancet. 2004;363(9426):2022-31. [pmid: 15207952].
Kizer JR, Dahlof B, Kjeldsen SE, et al. Stroke reduction in hypertensive adults with cardiac hypertrophy randomized to losartan versus atenolol: the Losartan Intervention For Endpoint reduction in hypertension study. Hypertension. 2005;45(1):46-52. [pmid: 15583076].
Kjeldsen SE, Dahlof B, Devereux RB, et al. Effects of losartan on cardiovascular morbidity and mortality in patients with isolated systolic hypertension and left ventricular hypertrophy: a Losartan Intervention for Endpoint Reduction (LIFE) substudy. JAMA. 2002;288(12):1491-8. [pmid: 12243636].
Kumagai H, Hayashi K, Kumamaru H, et al. Amlodipine is comparable to angiotensin-converting enzyme inhibitor for long-term renoprotection in hypertensive patients with renal dysfunction: a one-year, prospective, randomized study. Am J Hypertens. 2000;13(9):980-5. [pmid: 10981547].
Kuperstein R, Sasson Z. Effects of antihypertensive therapy on glucose and insulin metabolism and on left ventricular mass: A randomized, double-blind, controlled study of 21 obese hypertensives. Circulation. 2000;102(15):1802-6. [pmid: 11023935].
Lakshman MR, Reda DJ, Materson BJ, et al. Diuretics and beta-blockers do not have adverse effects at 1 year on plasma lipid and lipoprotein profiles in men with hypertension. Department of Veterans Affairs Cooperative Study Group on Antihypertensive Agents. Arch Intern Med. 1999;159(6):551-8. [pmid: 10090111].
Lea J, Greene T, Hebert L, et al. The relationship between magnitude of proteinuria reduction and risk of end-stage renal disease: results of the African American study of kidney disease and hypertension. Arch Intern Med. 2005;165(8):947-53. [pmid: 15851648].
Lewis CE, Grandits A, Flack J, et al. Efficacy and tolerance of antihypertensive treatment in men and women with stage 1 diastolic hypertension. Results of the Treatment of Mild Hypertension Study. Arch Intern Med. 1996;156(4):377-85. [pmid: 8607723].
Lewis EJ, Hunsicker LG, Clarke WR, et al. Renoprotective effect of the angiotensin-receptor antagonist irbesartan in patients with nephropathy due to type 2 diabetes. N Engl J Med. 2001;345(12):851-60. [pmid: 11565517].
Lindholm LH, Ibsen H, Borch-Johnsen K, et al. Risk of new-onset diabetes in the Losartan Intervention For Endpoint reduction in hypertension study. J Hypertens. 2002;20(9):1879-86. [pmid: 12195132].
Lindholm LH, Ibsen H, Dahlof B, et al. Cardiovascular morbidity and mortality in patients with diabetes in the Losartan Intervention For Endpoint reduction in hypertension study (LIFE): a randomised trial against atenolol. Lancet. 2002;359(9311):1004-10. [pmid: 11937179].
Lithell H, Hansson L, Skoog I, et al. The Study on Cognition and Prognosis in the Elderly (SCOPE): principal results of a randomized double-blind intervention trial. J Hypertens. 2003;21(5):875-86. [pmid: 12714861].
Lithell H, Hansson L, Skoog I, et al. The Study on COgnition and Prognosis in the Elderly (SCOPE); outcomes in patients not receiving add-on therapy after randomization. J Hypertens. 2004;22(8):1605-12. [pmid: 15257185].
Malmqvist K, Ohman KP, Lind L, et al. Long-term effects of irbesartan and atenolol on the renin-angiotensin-aldosterone system in human primary hypertension: the Swedish Irbesartan Left Ventricular Hypertrophy Investigation versus Atenolol (SILVHIA). J Cardiovasc Pharmacol. 2003;42(6):719-26. [pmid: 14639093].
Massie BM. What is the meaning of LIFE? Implications of the Losartan Intervention for Endpoint reduction in hypertension trial for heart failure physicians. J Card Fail. 2002;8(4):197-201. [pmid: 12397565].
Neaton JD, Grimm RH Jr, Prineas RJ, et al. Treatment of Mild Hypertension Study. Final results. Treatment of Mild Hypertension Study Research Group. JAMA. 1993;270(6):713-24. [pmid: 8336373].
Nielsen FS, Rossing P, Gall MA, et al. Impact of lisinopril and atenolol on kidney function in hypertensive NIDDM subjects with diabetic nephropathy. Diabetes. 1994;43(9):1108-13. [pmid: 8070610].
Nielsen FS, Rossing P, Gall MA, et al. Long-term effect of lisinopril and atenolol on kidney function in hypertensive NIDDM subjects with diabetic nephropathy. Diabetes. 1997;46(7):1182-8. [pmid: 9200654].
Olsen MH, Fossum E, Hoieggen A, et al. Long-term treatment with losartan versus atenolol improves insulin sensitivity in hypertension: ICARUS, a LIFE substudy. J Hypertens. 2005;23(4):891-8. [pmid: 15775796].
Papademetriou V, Farsang C, Elmfeldt D, et al. Stroke prevention with the angiotensin II type 1-receptor blocker candesartan in elderly patients with isolated systolic hypertension: the Study on Cognition and Prognosis in the Elderly (SCOPE). J Am Coll Cardiol. 2004;44(6):1175-80. [pmid: 15364316].
Patel V, Rassam SM, Chen HC, et al. Effect of angiotensin-converting enzyme inhibition with perindopril and beta-blockade with atenolol on retinal blood flow in hypertensive diabetic subjects. Metabolism. 1998;47(12 Suppl 1):28-33. [pmid: 9867068].
Preston RA, Materson BJ, Reda DJ, et al. Proteinuria in mild to moderate hypertension: results of the VA cooperative study of six antihypertensive agents and placebo. Department of Veterans Affairs Cooperative Study Group on Antihypertensive Agents. Clin Nephrol. 1997;47(5):310-5. [pmid: 9181278].
PROGRESS Collaborative Group. Randomised trial of a perindopril-based blood-pressure-lowering regimen among 6,105 individuals with previous stroke or transient ischaemic attack. [erratum appears in Lancet 2001 Nov 3;358(9292):1556][summary for patients in Can Fam Physician. 2002 Oct;48:1625-9; PMID: 12474869]. Lancet. 2001;358(9287):1033-41. [pmid: 11589932].
Rahman M, Pressel S, Davis BR, et al. Renal outcomes in high-risk hypertensive patients treated with an angiotensin-converting enzyme inhibitor or a calcium channel blocker vs a diuretic: a report from the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). Arch Intern Med. 2005;165(8):936-46. [pmid: 15851647].
Rahman M, Pressel S, Davis BR, et al. Cardiovascular outcomes in high-risk hypertensive patients stratified by baseline glomerular filtration rate. summary for patients in Ann Intern Med. 2006 Feb 7;144(3):I33; PMID: 16461958. Ann Intern Med. 2006;144(3):172-80. [pmid: 16461961].
Reims HM, Kjeldsen SE, Brady WE, et al. Alcohol consumption and cardiovascular risk in hypertensives with left ventricular hypertrophy: the LIFE study. J Hum Hypertens. 2004;18(6):381-9. [pmid: 15103313].
Reims HM, Oparil S, Kjeldsen SE, et al. Losartan benefits over atenolol in non-smoking hypertensive patients with left ventricular hypertrophy: the LIFE study. Blood Press. 2004;13(6):376-84. [pmid: 15771223].
Remuzzi G, Ruggenenti P, Perna A, et al. Continuum of renoprotection with losartan at all stages of type 2 diabetic nephropathy: a post hoc analysis of the RENAAL trial results. J Am Soc Nephrol. 2004;15(12):3117-25. [pmid: 15579515].
Reneland R, Alvarez E, Andersson PE, et al. Induction of insulin resistance by beta-blockade but not ACE-inhibition: long-term treatment with atenolol or trandolapril. J Hum Hypertens. 2000;14(3):175-80. [pmid: 10694831].
Skoog I, Lithell H, Hansson L, et al. Effect of baseline cognitive function and antihypertensive treatment on cognitive and cardiovascular outcomes: Study on COgnition and Prognosis in the Elderly (SCOPE). Am J Hypertens. 2005;18(8):1052-9. [pmid: 16109319].
Tatti P, Pahor M, Byington RP, et al. Outcome results of the Fosinopril Versus Amlodipine Cardiovascular Events Randomized Trial (FACET) in patients with hypertension and NIDDM. Diabetes Care. 1998;21(4):597-603. [pmid: 9571349].
Trenkwalder P, Elmfeldt D, Hofman A, et al. The Study on COgnition and Prognosis in the Elderly (SCOPE) - major CV events and stroke in subgroups of patients. Blood Press. 2005;14(1):31-7. [pmid: 15823945].
van Dijk MA, Breuning MH, Duiser R, et al. No effect of enalapril on progression in autosomal dominant polycystic kidney disease. Nephrol Dial Transplant. 2003;18(11):2314-20. [pmid: 14551359].
van Essen GG, Apperloo AJ, Rensma PL, et al. Are angiotensin converting enzyme inhibitors superior to beta blockers in retarding progressive renal function decline?. Kidney Int Suppl. 1997;63:S58-62. [pmid: 9407423].
Velussi M, Brocco E, Frigato F, et al. Effects of cilazapril and amlodipine on kidney function in hypertensive NIDDM patients. Diabetes. 1996;45(2):216-22. [pmid: 8549868].
Wachtell K, Hornestam B, Lehto M, et al. Cardiovascular morbidity and mortality in hypertensive patients with a history of atrial fibrillation: The Losartan Intervention For End Point Reduction in Hypertension (LIFE) study. J Am Coll Cardiol. 2005;45(5):705-11. [pmid: 15734614].
Wachtell K, Lehto M, Gerdts E, et al. Angiotensin II receptor blockade reduces new-onset atrial fibrillation and subsequent stroke compared to atenolol: the Losartan Intervention For End Point Reduction in Hypertension (LIFE) study. J Am Coll Cardiol. 2005;45(5):712-9. [pmid: 15734615].
Webster J, Petrie JC, Robb OJ, et al. Enalapril in moderate to severe hypertension: a comparison with atenolol. Br J Clin Pharmacol. 1986;21(5):489-95. [pmid: 3013265].
Wright JT Jr, Bakris G, Greene T, et al. Effect of blood pressure lowering and antihypertensive drug class on progression of hypertensive kidney disease: results from the AASK trial. JAMA. 2002;288(19):2421-31. [pmid: 12435255].