# Exact Search Strings

## Search Strategies Used for the Present (Updated) Report

### MEDLINE Search—Last Run December 23, 2010

1. (losartan or valsartan or telmisartan or eprosartan or candesartan or irbesartan or olmesartan).mp.
2. losartan/
3. exp angiotensin II type 1 receptor blockers/ or exp Receptors, Angiotensin/ai [Antagonists & Inhibitors]
4. (cozaar or micardis or atacand or tevetan or avapro or benicar or diovan).mp.
5. or/1-4
6. (quinapril or perindopril or ramipril or captopril or enalapril or benazepril or trandolapril or fosinopril or moexipril or enalaprilat or cilazapril or saralasin or teprotide).mp.
7. angiotensin-converting enzyme inhibitors/ or captopril/ or cilazapril/ or enalapril/ or enalaprilat/ or fosinopril/ or lisinopril/ or perindopril/ or ramipril/ or saralasin/ or teprotide/
8. 6 or 7
9. 5 and 8
10. limit 9 to yr="2006 - current"
11. limit 10 to english language
12. exp hypertension/dt
13. 11 and 12
14. randomized controlled trial.pt.
15. controlled clinical trial.pt.
16. Randomized Controlled Trials/
17. Random Allocation/
18. Double-Blind Method/
19. Single-Blind Method/
20. or/14-19
21. Animal/ not Human/
22. 20 not 21
23. clinical trial.pt.
24. exp Clinical Trial/
25. (clinic$ adj25 trial$).tw.
26. ((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).tw.
27. Placebos/
28. placebo$.tw.
29. random$.tw.
30. Research Design/
31. (latin adj square).tw.
32. or/23-31
33. 32 not 21
34. Comparative Study/
35. exp Evaluation Studies/
36. Follow-Up Studies/
37. Prospective Studies/
38. (control$ or prospectiv$ or volunteer$).tw.
39. Cross-Over Studies/
40. or/34-39
41. 40 not 21
42. 22 or 33 or 41
43. 13 and 42
44. limit 43 to abstracts
45. (aliskiren or tekturna).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier]
46. (renin inhibitor or renin inhibitors).mp. [mp=title, original title, abstract, name of substance word, subject heading word, unique identifier]
47. renin/ai
48. or/45-47
49. 5 and 48
50. 49 and 42 and 12
51. 8 and 48
52. 51 and 42 and 12
53. 50 or 52
54. limit 53 to english language
55. 43 or 54

### Embase Search—Last Run December 23, 2010

1. ‘benazepril’/exp OR ‘captopril’/exp OR ‘enalapril’/exp OR ‘enalaprilat’/exp OR ‘fosinopril’/exp OR ‘lisinopril’/exp OR ‘moexipril’/exp OR ‘perindopril’/exp OR ‘quinapril’/exp OR ‘ramipril’/exp OR ‘trandolapril’/exp OR ‘lotensin’/exp OR ‘capoten’/exp OR ‘vasotec’/exp OR ‘monopril’/exp OR ‘prinivil’/exp OR ‘zestril’/exp OR ‘univasc’/exp OR ‘aceon’/exp OR ‘accupril’/exp OR ‘altace’/exp OR ‘mavik’/exp OR ‘angiotensin converting enzyme inhibitors’/exp AND (‘candesartan’/exp AND cilexetil OR ‘eprosartan’/exp OR ‘irbesartan’/exp OR ‘losartan’/exp OR ‘olmesartan’/exp AND medoxomil OR ‘telmisartan’/exp OR ‘valsartan’/exp OR ‘atacand’/exp OR ‘teveten’/exp OR ‘avapro’/exp OR ‘cozaar’/exp OR ‘benicar’/exp OR ‘micardis’/exp OR ‘diovan’/exp OR ‘angiotensin ii type 1 receptor blockers’/exp) AND [2006-2010]/py
2. ‘benazepril’/exp OR ‘captopril’/exp OR ‘enalapril’/exp OR ‘enalaprilat’/exp OR ‘fosinopril’/exp OR ‘lisinopril’/exp OR ‘moexipril’/exp OR ‘perindopril’/exp OR ‘quinapril’/exp OR ‘ramipril’/exp OR ‘trandolapril’/exp OR ‘lotensin’/exp OR ‘capoten’/exp OR ‘vasotec’/exp OR ‘monopril’/exp OR ‘prinivil’/exp OR ‘zestril’/exp OR ‘univasc’/exp OR ‘aceon’/exp OR ‘accupril’/exp OR ‘altace’/exp OR ‘mavik’/exp OR ‘angiotensin converting enzyme inhibitors’/exp AND (‘aliskiren’/exp OR ‘tekturna’/exp OR (direct AND ‘renin’/exp AND inhibitors))
3. ‘candesartan’/exp AND cilexetil OR ‘eprosartan’/exp OR ‘irbesartan’/exp OR ‘losartan’/exp OR ‘olmesartan’/exp AND medoxomil OR ‘telmisartan’/exp OR ‘valsartan’/exp OR ‘atacand’/exp OR ‘teveten’/exp OR ‘avapro’/exp OR ‘cozaar’/exp OR ‘benicar’/exp OR ‘micardis’/exp OR ‘diovan’/exp OR ‘angiotensin ii type 1 receptor blockers’/exp AND (‘aliskiren’/exp OR ‘tekturna’/exp OR (direct AND ‘renin’/exp AND inhibitors))
4. #1 OR #2 OR #3
5. ‘hypertension’/exp
6. #4 AND #5
7. #4 AND #5 AND ([cochrane review]/lim OR [controlled clinical trial]/lim OR [meta analysis]/lim OR [randomized controlled trial]/lim OR [systematic review]/lim) AND ([article]/lim OR [article in press]/lim OR [conference abstract]/lim OR [conference paper]/lim OR [conference review]/lim OR [review]/lim) AND [humans]/lim AND [english]/lim AND [embase]/lim

## Search Strategies Used for the Original 2007 Report

### MEDLINE Search 1

Used to identify studies of (a) ACEIs vs. ARBs and (b) ARBs vs. other (non-ACEI) comparators. ACEIs vs. ARBs portion of strategy also used to search the Cochrane Central Register of Controlled Trials.

Database: Ovid MEDLINE <1966 to May Week 3 2006>

Search Strategy:

--------------------------------------------------------------------------------

1. (losartan or valsartan or telmisartan or eprosartan or candesartan or irbesartan or olmesartan).mp. (7801)
2. losartan/ (3821)
3. angiotensin II type 1 receptor blockers/ (1417)
4. (cozaar or micardis or atacand or tevetan or avapro or benicar or diovan).mp. (89)
5. or/1-4 (8186)
6. (quinapril or perindopril or ramipril or captopril or enalapril or benazepril or trandolapril or fosinopril or moexipril or enalaprilat or cilazapril).mp. (20419)
7. angiotensin-converting enzyme inhibitors/ or captopril/ or cilazapril/ or enalapril/ or enalaprilat/ or fosinopril/ or lisinopril/ or perindopril/ or ramipril/ (29181)
8. 6 or 7 (31620)
9. 5 and 8 (2561)
10. limit 9 to yr="1989 - 2006" (2561)
11. limit 10 to humans (1570)
12. limit 11 to english language (1302)
13. exp hypertension/dt (43028)
14. 12 and 13 (501)
15. randomized controlled trial.pt. (225487)
16. controlled clinical trial.pt. (73200)
17. Randomized Controlled Trials/ (45397)
18. Random Allocation/ (57318)
19. Double-Blind Method/ (88071)
20. Single-Blind Method/ (10138)
21. or/15-20 (382640)
22. Animal/ not Human/ (3011569)
23. 21 not 22 (360978)
24. clinical trial.pt. (447512)
25. exp Clinical Trials/ (188054)
26. (clinic$ adj25 trial$).tw. (122637)
27. ((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).tw. (84242)
28. Placebos/ (25150)
29. placebo$.tw. (97000)
30. random$.tw. (351176)
31. Research Design/ (44423)
32. (latin adj square).tw. (2271)
33. or/24-32 (817761)
34. 33 not 22 (760307)
35. 34 not 23 (412905)
36. Comparative Study/ (1296809)
37. exp Evaluation Studies/ (574715)
38. Follow-Up Studies/ (327165)
39. Prospective Studies/ (209742)
40. (control$ or prospectiv$ or volunteer$).tw. (1678468)
41. Cross-Over Studies/ (18169)
42. or/36-41 (3339392)
43. 42 not 22 (2575440)
44. 43 not (23 or 35) (2038591)
45. 23 or 35 or 44 (2812474)
46. 14 and 45 (421)
47. limit 46 to abstracts (383)
48. 46 not 47 (38)
49. 5 and 13 and 23 (812)
50. 5 and 13 and 15 (577)
51. limit 50 to humans (576)
52. limit 51 to english language (547)
53. limit 52 to abstracts (526)
54. 53 not 47 (355)
55. 47 or 54 (738)
56. from 55 keep 1-738 (738)

--------------------------------------------------------------------------------

### MEDLINE Search 2

Used to identify studies of ACEIs vs. atenolol or amlodipine.

Database: Ovid MEDLINE <1966 to June Week 2 2006>

Search Strategy:

--------------------------------------------------------------------------------

1. (losartan or valsartan or telmisartan or eprosartan or candesartan or irbesartan or olmesartan).mp. (7907)
2. losartan/ (3866)
3. angiotensin II type 1 receptor blockers/ (1495)
4. (cozaar or micardis or atacand or tevetan or avapro or benicar or diovan).mp. (89)
5. or/1-4 (8317)
6. (quinapril or perindopril or ramipril or captopril or enalapril or benazepril or trandolapril or fosinopril or moexipril or enalaprilat or cilazapril).mp. (20515)
7. angiotensin-converting enzyme inhibitors/ or captopril/ or cilazapril/ or enalapril/ or enalaprilat/ or fosinopril/ or lisinopril/ or perindopril/ or ramipril/ (29405)
8. 6 or 7 (31862)
9. 5 and 8 (2616)
10. limit 9 to yr="1989 - 2006" (2616)
11. limit 10 to humans (1616)
12. limit 11 to english language (1344)
13. exp hypertension/dt (43234)
14. 12 and 13 (513)
15. randomized controlled trial.pt. (227233)
16. controlled clinical trial.pt. (73582)
17. Randomized Controlled Trials/ (46059)
18. Random Allocation/ (57572)
19. Double-Blind Method/ (88623)
20. Single-Blind Method/ (10243)
21. or/15-20 (385737)
22. Animal/ not Human/ (3039204)
23. 21 not 22 (363780)
24. clinical trial.pt. (449329)
25. exp Clinical Trials/ (189510)
26. (clinic$ adj25 trial$).tw. (124237)
27. ((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).tw. (84782)
28. Placebos/ (25242)
29. placebo$.tw. (97782)
30. random$.tw. (355789)
31. Research Design/ (44740)
32. (latin adj square).tw. (2283)
33. or/24-32 (825939)
34. 33 not 22 (767683)
35. 34 not 23 (417884)
36. Comparative Study/ (1313583)
37. exp Evaluation Studies/ (581443)
38. Follow-Up Studies/ (330247)
39. Prospective Studies/ (211855)
40. (control$ or prospectiv$ or volunteer$).tw. (1701806)
41. Cross-Over Studies/ (18356)
42. or/36-41 (3382854)
43. 42 not 22 (2610193)
44. 43 not (23 or 35) (2068318)
45. 23 or 35 or 44 (2849982)
46. 14 and 45 (430)
47. limit 46 to abstracts (392)
48. 46 not 47 (38)
49. 5 and 13 and 23 (826)
50. 5 and 13 and 15 (589)
51. limit 50 to humans (588)
52. limit 51 to english language (559)
53. limit 52 to abstracts (538)
54. 53 not 47 (363)
55. 47 or 54 (755)
56. 8 and 13 and 45 (5143)
57. amlodipine.mp. or Amlodipine/ (2102)
58. atenolol.mp. or Atenolol/ (5762)
59. 57 or 58 (7736)
60. 8 and 59 (1120)
61. 60 and 13 (767)
62. 61 and 45 (678)
63. 61 and 23 (501)
64. 61 and 15 (388)
65. limit 64 to humans (388)
66. limit 65 to english language (369)
67. limit 66 to abstracts (354)
68. from 67 keep 1-354 (354)

--------------------------------------------------------------------------------

### MEDLINE Search 3

Used to identify studies of ACEIs vs. placebo published after the June 2005 Drug Class Review on Angiotensin Converting Enzyme Inhibitors.^*^

* Chou R, Helfand M, Carson S. Drug Class Review on Angiotensin Converting Enzyme Inhibitors. Final Report. June 2005. Available at: www.ohsu.edu/drugeffectiveness/reports/final.cfm. Accessed 17 August 2006.

Database: Ovid MEDLINE <1966 to June Week 4 2006>

Search Strategy:

--------------------------------------------------------------------------------

1. (losartan or valsartan or telmisartan or eprosartan or candesartan or irbesartan or olmesartan).mp. (7931)
2. losartan/ (3878)
3. angiotensin II type 1 receptor blockers/ (1523)
4. (cozaar or micardis or atacand or tevetan or avapro or benicar or diovan).mp. (90)
5. or/1-4 (8352)
6. (quinapril or perindopril or ramipril or captopril or enalapril or benazepril or trandolapril or fosinopril or moexipril or enalaprilat or cilazapril).mp. (20553)
7. angiotensin-converting enzyme inhibitors/ or captopril/ or cilazapril/ or enalapril/ or enalaprilat/ or fosinopril/ or lisinopril/ or perindopril/ or ramipril/ (29480)
8. 6 or 7 (31944)
9. 5 and 8 (2631)
10. limit 9 to yr="1989 - 2006" (2631)
11. limit 10 to humans (1629)
12. limit 11 to english language (1356)
13. exp hypertension/dt (43305)
14. 12 and 13 (516)
15. randomized controlled trial.pt. (227810)
16. controlled clinical trial.pt. (73653)
17. Randomized Controlled Trials/ (46324)
18. Random Allocation/ (57680)
19. Double-Blind Method/ (88793)
20. Single-Blind Method/ (10281)
21. or/15-20 (386780)
22. Animal/ not Human/ (3043394)
23. 21 not 22 (364697)
24. clinical trial.pt. (449647)
25. exp Clinical Trials/ (190053)
26. (clinic$ adj25 trial$).tw. (124749)
27. ((singl$ or doubl$ or trebl$ or tripl$) adj (mask$ or blind$)).tw. (84961)
28. Placebos/ (25278)
29. placebo$.tw. (98008)
30. random$.tw. (356966)
31. Research Design/ (44861)
32. (latin adj square).tw. (2289)
33. or/24-32 (828165)
34. 33 not 22 (769721)
35. 34 not 23 (419156)
36. Comparative Study/ (1316751)
37. exp Evaluation Studies/ (582995)
38. Follow-Up Studies/ (331073)
39. Prospective Studies/ (212521)
40. (control$ or prospectiv$ or volunteer$).tw. (1706292)
41. Cross-Over Studies/ (18430)
42. or/36-41 (3391311)
43. 42 not 22 (2617037)
44. 43 not (23 or 35) (2073600)
45. 23 or 35 or 44 (2857453)
46. 14 and 45 (432)
47. limit 46 to abstracts (393)
48. 46 not 47 (39)
49. 5 and 13 and 23 (829)
50. 5 and 13 and 15 (590)
51. limit 50 to humans (589)
52. limit 51 to english language (560)
53. limit 52 to abstracts (539)
54. 53 not 47 (364)
55. 47 or 54 (757)
56. 8 and 13 and 45 (5155)
57. amlodipine.mp. or Amlodipine/ (2108)
58. atenolol.mp. or Atenolol/ (5772)
59. 57 or 58 (7752)
60. 8 and 59 (1123)
61. 60 and 13 (768)
62. 61 and 45 (679)
63. 61 and 23 (502)
64. 61 and 15 (389)
65. limit 64 to humans (389)
66. limit 65 to english language (370)
67. limit 66 to abstracts (355)
68. from 67 keep 1-354 (354)
69. 56 and (28 or 29) (1286)
70. limit 69 to humans (1286)
71. limit 70 to english language (1154)
72. limit 71 to abstracts (1150)
73. (2005$ or 2006$).ed. (974282)
74. 72 and 73 (52)
75. from 74 keep 1-52 (52)

--------------------------------------------------------------------------------