# Appendixes

Appendix A Exact Search Strings

Appendix B Methods for Reviewing Indirect Comparison Studies

Appendix C Abstract and Full-Text Screening Criteria

Appendix D Data Abstraction Form

Appendix E Evidence Table

Appendix F Applicability Criteria

Appendix G List of Excluded Direct Comparator Studies

Appendix H Analyses of Potential Publication Bias