# Acronyms and Abbreviations

ACE: angiotensin-converting enzyme
ACEI(s): angiotensin-converting enzyme inhibitor(s)
AHRQ: Agency for Healthcare Research and Quality
ARB(s): angiotensin II receptor blocker(s)/antagonist(s)
AT_1_: angiotensin specific receptor
CER: Comparative Effectiveness Review
CRD: Centre for Reviews and Dissemination
DBP: diastolic blood pressure
EF: ejection fraction
EPC: Evidence-based Practice Centers
ESRD: end-stage renal disease
GFR: glomerular filtration rate
HbA1c: glycated hemoglobin
HCTZ: hydrochlorothiazide
HDL: high-density lipoprotein
LDL: low-density lipoprotein
LV: left ventricular
LVEF: left ventricular ejection fraction
LVH: left ventricular hypertrophy
LVMI: left ventricular mass index
MeSH: Medical Subject Headings
MI: myocardial infarction
RCT: randomized controlled trial
SBP: systolic blood pressure
SD: standard deviation
SF-36: Medical Outcomes Study 36-Item Short Form Health Survey
SRC: Scientific Resource Center
TC: total cholesterol
TG: triglyceride
UAE: urinary albumin excretion
USPSTF: U.S. Preventive Services Task Force