# Technical Expert Panel

We extend our appreciation to our Technical Expert Panel: William L. Bruning, J.D., M.B.A.; Allen Daniels, Ed.D.; Ronald M. Glick, M.D.; Mustafa M. Husain, M.D.; Sarah H. Lisanby, M.D.; Glenda M. MacQueen, Ph.D., M.D.; David L. Shern, Ph.D.; Michael Edward Thase, M.D.; and John W. Williams, Jr., M.D. All provided thoughtful advice and input during our research process.

William L. Bruning, J.D., M.B.A.

President and CEO

Mid-America Coalition on Health Care

Kansas City, Missouri

Allen Daniels, Ed.D.

Vice President of Scientific Affairs

Depression and Bipolar Support Alliance

Chicago, Illinois

Ronald M. Glick, M.D.

Medical Director of Center for Integrative Medicine, University of Pittsburgh Medical Center

Department of Psychiatry

University of Pittsburgh Medical Center

Pittsburgh, Pennsylvania

Mustafa M. Husain, M.D.

Professor of Psychiatry and Internal Medicine Director

Neurostimulation Research Lab Chief

UT Southwestern Medical Center at Dallas, Texas

Sarah H. Lisanby, M.D.

Director, Division of Brain Stimulation & Therapeutic Modulation

Columbia University College of Physicians and Surgeons

New York State Psychiatric Institute

New York, New York

Glenda M. MacQueen, Ph.D., M.D.

Head, Dept. Mood Disorders Research Program

Psychiatry and Behavioral Neurosciences

McMasters University

Hamilton, Ontario

David L. Shern, Ph.D.

President and CEO

Mental Health America

Alexandria, Virginia

Michael Edward Thase, M.D.

Professor of Psychiatry

Mood and Anxiety Disorders Treatment and Research Program

University of Pennsylvania

John W. Williams, Jr., M.D.

Former Director, Duke Evidence-based Practice Center

Duke University and Durham VA Medical Center

Durham, North Carolina