# Results

## Introduction

This chapter presents the results of our synthesis of the evidence on all six key questions (KQs, summarized in Table 6) about nonpharmacologic interventions for treating patients with treatment-resistant depression (TRD). To summarize, for all KQs except KQ 1, we are concerned with four major nonpharmacologic interventions: electroconvulsive therapy (ECT), repetitive transcranial magnetic stimulation (rTMS), vagus nerve stimulation (VNS), and cognitive behavioral therapy or interpersonal psychotherapy (CBT or IPT). As noted in Table 6, KQ 1b asks about pharmacologic interventions in patients who have two or more previous treatment failures.

Table 6 Key questions about treatment-resistant depression (TRD)

Key Questions
KQ 1a. Efficacy of nonpharmacologic interventions for acute-phase TRD (response or remission) KQ 1b. Efficacy of pharmacologic interventions for acute-phase TRD (response or remission), for patients with two or more prior treatment failures
KQ 2. Efficacy for maintaining response or remission (e.g., preventing relapse or recurrence)
KQ 3. Efficacy for acute-phase TRD as a function of particular symptom subtypes (e.g., catatonia or psychosis)
KQ 4. Harms of nonpharmacologic interventions (i.e., safety, adverse events, or adherence issues)
KQ 5. Efficacy or harms of nonpharmacologic treatments for selected subgroups defined by sociodemographic characteristics or coexisting conditions
KQ 6. Health-related outcomes of nonpharmacologic treatments (e.g., quality of life)

This chapter is organized as follows: first by KQ, second by intervention comparison, third by type of treatment failure (i.e., tier), and then by major depressive disorder (MDD) or MDD and bipolar study populations. In addition, according to the specifications from the Agency for Healthcare Research and Quality for comparative effectiveness reviews, within each KQ section, we present an overview, then key points, and finally detailed analyses. Finally, as explained in the Methods chapter, we graded the strength of evidence for all major comparisons and outcomes. We provide our readers with the strength of evidence findings for TRD (Tier 1 studies) in the Overview sections for each KQ.

We focus in this chapter chiefly on trials, which can be head-to-head investigations or trials with control arms involving sham procedures or, for behavioral interventions, various forms of “usual care” that can include physician (psychiatrist) visits, medications, or both. For KQ 4 on harms, we also include observational studies. Evidence tables for all studies are presented in Appendix E.

We include information only on studies for which our quality ratings were good or fair; most studies were rated fair, so we specifically call out quality ratings only for good trials or studies. Poor-quality studies are listed in Appendix G; in the very few cases in which a poor-quality study may have had the only relevant information on a major comparison or outcome, we will cite information about statistically significant findings in the detailed analysis text. Summary tables in the detailed analyses subsections have only good or fair quality studies.

We identified 2,444 citations from searches across databases. Additionally, we detected 310 articles from manually reviewing the reference lists of pertinent review articles. Figure 4 documents the disposition of the 79 articles in this review. Of the total 2,754 abstracts screened, 1,896 citations were excluded. Working from 858 articles retrieved for full review, 779 were excluded at this stage (Appendix D). Of the studies excluded at the full review, 269 were excluded for no or wrong comparison, 249 were excluded for including the wrong population, 137 were excluded for wrong publication type, 53 were excluded due to the analysis of outcomes not of interest, 29 were excluded for performing analysis on an intervention not of interest, 27 were excluded for a publishing date prior to 1980, and 15 were excluded because the study was the wrong study design. We included 79 published articles reporting on 64 studies: 62 randomized controlled trials (RCTs) (77 articles) and 2 observational studies (2 articles). Evidence tables for included studies, by key question, can be found in Appendix E.

Figure 4 PRISMA tree/disposition of articles

*Articles were included for more than one KQ

Figure 4 is a PRISMA tree that documents the disposition of the articles reviewed for this review. There were 2,444 citations identified from searches across databases. Additionally, 310 articles were detected from manually reviewing the reference lists of pertinent review articles. Of the total 2,754 abstracts screened, 1,896 citations were excluded. Working from 858 articles retrieved for full review, 779 were excluded at this stage. Of the studies excluded at the full review 269 were excluded for no or wrong comparison, 249 were excluded for including the wrong population, 137 were excluded for wrong publication type, 53 were excluded due to the analysis of outcomes not of interest, 29 were excluded for performing analysis on an intervention not of interest, 27 were excluded for a publishing date prior to 1980, and 15 were excluded because the study was the wrong study design. We included 79 published articles reporting on 64 studies: 62 randomized controlled trials (RCTs) (77 articles) and 2 observational studies (2 articles). Most included studies were relevant for more than one KQ. For KQ 1a a total of 40 studies (55 articles) were included. Of these studies, 8 (19 articles) were rated as good and 29 (32 articles) were rated fair quality for internal validity. KQ 1b included 18 studies (18 articles) of which 2 studies (2 articles) were rated as having good internal validity and 13 studies (13 articles) were rated as having fair internal validity. For KQ 2 a total of 12 studies (23 articles) were included. Of these studies, none were rated as good. Eleven studies in KQ 2 (22 articles) were rated as fair quality for internal validity. No studies with good or fair internal validity were identified for KQ 3. For KQ 4a a total of 14 studies (25 articles) were included. Of these studies, 2 studies (5 articles) were rated as good. Nine studies in KQ 4a (15 articles) were rated as fair quality for internal validity. KQ 4b included 19 studies (28 articles) of which 3 studies (6 articles) were rated as having good internal validity and 5 studies (10 articles) were rated as having fair internal validity. For KQ 4c a total of 21 studies (34 articles) were included. Of these studies, 6 studies (14 articles) were rated as good. Fifteen studies in KQ 4c (20 articles) were rated as fair quality for internal validity. KQ 4d included 28 studies overall (42 articles) of which 6 studies were good (14 articles) and 21 studies (27 articles) were rated as fair. KQ 5 included a total of 7 studies (8 articles). No studies were rated as good and 5 studies (6 articles) were rated as fair. For KQ 6 a total of 8 studies (13 articles) were included, seven of which were rated as having fair internal validity while no studies were rated as having good internal validity. Reasons for exclusion were based on eligibility criteria or methodological criteria. Studies that originally met eligibility criteria but were later rated as poor quality for internal validity. Eight distinct studies were excluded from consideration for any of the KQs because of poor quality. Eleven studies were included in the review that were rated as fair or good quality and included certain key questions (e.g., KQ 1a), but were rated as poor for other key questions and hence excluded (e.g., KQ 4b). For KQ 1a, 3 studies (4 articles) were rated as poor. KQ 2, KQ 3, and KQ 6 each rated one study as poor. KQ 1b excluded 3 studies for poor internal validity. Of the studies applicable to KQ 4a, 3 studies (5 articles) were rated as having poor internal validity. KQ 4b excluded 11 studies (12 articles) for poor internal validity. For KQ 4c, no poor studies were identified. One study was rated as having poor internal validity in KD 4d. KQ 5 excluded 2 studies (2 articles) for poor internal validity. The main reason for rating as poor of studies was due to poor reporting of methodology.

Of the 79 included articles, 17 (22 percent) were supported by pharmaceutical or device manufacturers; 48 (61 percent) were funded by governmental or independent funds. We could not determine the source of support for 14 (17 percent) studies.

Of the included studies, there were 17 head-to-head RCTs (19 articles): 7 studies (9 articles) were head-to-head RCTs of a non-pharmacologic intervention versus a nonpharmacologic intervention; 3 were head-to-head RCTs of a nonpharmacologic intervention versus a pharmacologic one; and 7 were head-to-head studies of a pharmacologic versus pharmacologic intervention. Further, there were 38 additional RTCs (50 articles) that were sham- or placebo-controlled, and 2 observational studies (2 articles). We excluded eight studies (eight articles) because of poor quality.

Most included studies were relevant for more than one KQ. For KQ 1a a total of 40 studies (55 articles) were included. Of these studies, 8 (19 articles) were rated as good and 29 (32 articles) were rated fair quality for internal validity. KQ 1b included 18 studies (18 articles), of which 2 studies (2 articles) were rated as having good internal validity and 13 studies (13 articles) were rated as having fair internal validity. For KQ 2, a total of 12 studies (23 articles) were included. Of these studies, none were rated as good. Eleven studies in KQ 2 (22 articles) were rated as fair quality for internal validity. No studies with good or fair internal validity were identified for KQ 3. For KQ 4a, a total of 14 studies (25 articles) were included. Of these studies, two studies (five articles) were rated as good. Nine studies in KQ 4a (15 articles) were rated as fair quality for internal validity. KQ 4b included 19 studies (28 articles), of which 3 studies (6 articles) were rated as having good internal validity and 5 studies (10 articles) were rated as having fair internal validity. For KQ 4c, a total of 21 studies (34 articles) were included. Of these studies, 6 studies (14 articles) were rated as good. Fifteen studies in KQ 4c (20 articles) were rated as fair quality for internal validity. KQ 4d included 28 studies overall (42 articles), of which 6 studies were good (14 articles) and 21 studies (27 articles) were rated as fair. KQ 5 included a total of seven studies (eight articles). No studies were rated as good, and five studies (six articles) were rated as fair. For KQ 6, a total of 8 studies (13 articles) were included, 7 of which were rated as having fair internal validity, while no studies were rated as having good internal validity.

Reasons for exclusion were based on eligibility criteria or methodological criteria. Studies that originally met eligibility criteria but were later rated as poor quality for internal validity are located in Appendix E. Eight distinct studies were excluded from consideration for any of the KQs because of poor quality. Eleven studies were included in the review that were rated as fair or good quality and included certain key questions (e.g., KQ 1a), but were rated as poor for other key questions and hence excluded (e.g., KQ 4b). For KQ 1a, three studies (four articles) were rated as poor. KQ 2, KQ 3, and KQ 6 each rated one study as poor. KQ 1b excluded three studies for poor internal validity. Of the studies applicable to KQ 4a, three studies (five articles) were rated as having poor internal validity. KQ 4b excluded 11 studies (12 articles) for poor internal validity. For KQ 4c, no poor studies were identified. One study was rated as having poor internal validity in KD 4d. KQ 5 excluded two studies (two articles) for poor internal validity. The main reason for rating as poor of studies was due to poor reporting of methodology.

## Key Question 1 Organization of Results

The presentation of KQ 1, which deals only with efficacy and effectiveness of interventions undertaken in acute phase treatment, is complex. Such clinical outcomes are one of a number of variables guiding the selection of therapy. Other considerations in acute phase treatment—such as effectiveness for subgroups, harms, and other health-related outcomes like quality of life—are addressed by KQs 3 through 6. KQ 2, in contrast, assesses the role of treatment selection in maintaining response or remission during continuation phase treatment.

Our primary focus is on comparisons of nonpharmacologic interventions—ECT, rTMS, VNS, and psychotherapy—presented as KQ 1a. We present evidence that stratifies first by which interventions are being compared, then by tier, and then by whether the population was MDD-only or MDD/bipolar mix. Within each tier, we attempt to assess the effect on outcomes of key PICOTS (patient population, intervention, comparison, outcome, and timeframe) elements: whether the population is MDD versus MDD/bipolar mix; whether treatment failure is required in the current episode; the level of depressive severity; treatment characteristics (e.g., number of treatment sessions, treatment location); and treatment strategy (e.g., whether patients switched to a new treatment or added a new treatment to augment their current treatment). We focus on Tier 1 TRD data first, and then we consider potentially relevant data from Tiers 2 and 3. We begin by reviewing this head-to-head literature.

Given the limited number of head-to-head comparisons available, we also review the nonpharmacologic interventions versus control to assess whether we might be able to extend our analyses through indirect comparison. Such indirect analyses require a suitable number of comparisons with placebo or sham groups across the interventions.

Next, in KQ 1b, we compare nonpharmacologic to pharmacologic interventions. We present the evidence in a similar order. First, we review head-to-head nonpharmacologic versus pharmacologic comparisons. Second, we review available pharmacologic versus pharmacologic literature addressing response to antidepressant management to provide a comparison of what might be expected with a next-step pharmacologic treatment for TRD. These comparisons involve only MDD-only, Tier 1 study populations. In reviewing the pharmacologic literature, we attempt to identify adequate control groups that would allow us to generate indirect measures of the relative outcomes of pharmacologic versus control interventions that we can compare to the nonpharmacologic effect sizes. Throughout KQ 1, we provide a qualitative synthesis of the evidence; this synthesis is paired with a quantitative analysis of this data when an adequate number of studies are identified.

Our main outcomes of interest are changes in depressive severity, rates of response, and rates of remission. Most studies report these outcomes using a version of the Hamilton Rating Scale for Depression (HAM-D), so we focus on this result; however, in the absence of HAM-D scores, we used Montgomery-Asberg Depression Rating Scale (MADRS), Beck Depression Inventory (BDI), or Quick Inventory of Depressive Symptomology (QIDS-SR) scores. In Table 7, information is provided for these scales. For each outcome, we report the results of appropriate statistical tests comparing results between groups. All statistics are based on an intention-to-treat analysis unless otherwise specified. In studies in which the mean change in depression severity or proportion of responders or remitters is not reported but in which sufficient information is provided to calculate these variables, we made the calculations and include this information in the tables. To assist the reader making comparisons between studies, the proportion of responders and remitters is shown as a function of the number of participants randomized (i.e., an intention-to-treat [ITT] analysis); statistical analyses calculated using a completers, per-protocol, or modified-ITT analysis are identified as such in the summary tables. We also categorized each population for depression severity using the chart described in Table 4 of the Methods section. We consider only studies assessed as good or fair quality.

Table 7 Abbreviations and full names of diagnostic scales and other instruments

Abbreviated Name | Complete Name of Measure or Instrument | Range of Scores | Improvement Denoted by
BDI | Beck Depression Inventory | 0-63 | Decrease
HAM-D_17_ | Hamilton Rating Scale for Depression – 17 item | 0-52 | Decrease
HAM-D_21_ | Hamilton Rating Scale for Depression – 21 item | 0-64 | Decrease
HAM-D_24_ | Hamilton Rating Scale for Depression – 24 item | 0-75 | Decrease
HAM-D_25_ | Hamilton Rating Scale for Depression – 25 item | 0-52 | Decrease
MADRS | Montgomery-Asberg Depression Rating Scale | 0-60 | Decrease
QID-SR | Quick Inventory of Depressive Symptomology – Self Report | 0-27 | Decrease

## Key Question 1a Nonpharmacologic Interventions—Overview of Head-to-Head Comparisons

Six head-to-head comparisons were available, four comparing ECT with rTMS and two comparing ECT with a combination of ECT plus rTMS (Table 8).

Table 8 Number of good- and fair-quality studies by comparison, tier, and diagnostic mix for KQ 1a

Comparison | Tier | MDD-Only | MDD and Bipolar Disorder
ECT versus rTMS | Tier 1 (≥ 2 treatment failures) | 1 | 0
ECT versus rTMS | Tier 2 (≥ 1 treatment failures) | 1 additional | 0
ECT versus rTMS | Tier 3 (probable treatment failures) | 0 | 2 additional
ECT versus ECT plus rTMS | Tier 1 (≥ 2 treatment failures) | 1 | 0
ECT versus ECT plus rTMS | Tier 3 (probable treatment failures) | 1 additional | 0

ECT = electroconvulsive therapy; MDD = major depressive disorder; rTMS = repetitive transcranial magnetic stimulation

Of the four studies (reported in six articles) that compared ECT with rTMS,58-63 only one was in a Tier 1 MDD population.58 Both this study and the single Tier 2 MDD study59 found no significant differences between groups. However, a good-quality Tier 3 MDD/bipolar mix study found a greater change in depressive symptomatology and higher response and remission rates in the ECT group.61,63 A second Tier 3 study rated fair supported these results showing higher response and remission rates in the ECT group.60

Of the two studies comparing ECT with a combination of ECT and rTMS, both were in an MDD population; one was in a Tier 1 study64 and the other was Tier 3.^65^ These two studies showed no difference in outcome between treatments.

All studies included patients with severe depression, and none required a failure in the current episode, preventing an assessment of the role of these variables on outcome. For studies comparing ECT with rTMS, the two Tier 3 studies favored ECT while the Tier 1 and 2 studies showed no difference in outcomes, but the limited number of studies limit observation of any true pattern.

We could not assess how type of treatment strategy affected outcomes because of the limited number of studies and the multiple types of treatment strategies used. Studies varied by whether the trial tested interventions as a switch strategy (switching from the current failed treatment to a new strategy),58,59,65,66 or an augmentation strategy (adding the new intervention to the current regimen).60-63 Finally, some studies compared combinations of treatments (such as ECT versus ECT plus rTMS).64,65

### Strength of Evidence: Tier 1 (TRD)

Strength of evidence assessments were made for three outcomes: change in depressive severity, response rates, and remission rates. One study provides a low strength of evidence that there were no differences in depressive severity, response rates, or remission rates between switching to ECT versus switching to rTMS (Table 9).58 Similarly, a second study provides a low strength of evidence that there were no differences in changes in depressive severity or between groups augmenting with ECT or with ECT plus rTMS (Table 10).64 Results from both studies are limited by a small sample size.

Table 9 Strength of Evidence: Efficacy of ECT versus rTMS

Outcome | Number of Studies; Subjects | Risk of bias Design/Quality | Consistency | Directness | Precision | Results and Strength of Evidence
Change in depressive severity | 1; 42 | Medium RCT 1 fair | Unknown | Direct | Imprecise | No significant difference Low
Response | 1; 42 | Medium RCT 1 fair | Unknown | Direct | Imprecise | No significant difference Low
Remission | 1; 42 | Medium RCT 1 fair | Unknown | Direct | Imprecise | No significant difference Low

ECT = electroconvulsive therapy; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation

Table 10 Strength of Evidence: Efficacy of ECT plus rTMS versus ECT

Outcome | Number of Studies; Subjects | Risk of bias Design/Quality | Consistency | Directness | Precision | Results and Strength of Evidence
Change in depressive severity | 1; 22 | Medium RCT 1 fair | Unknown | Indirect (compares combination to ECT rather than rTMS to ECT) | Imprecise | No significant difference Low
Response | 0; 0 | — | — | — | — | —
Remission | 1; 22 | Medium RCT 1 fair | Unknown | Indirect (compares combination to ECT rather than rTMS to ECT) | Imprecise | No significant difference Low

ECT = electroconvulsive therapy; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation

## Key Question 1a Nonpharmacologic Interventions–Key Points of Head-to-Head Comparisons

### Electroconvulsive Therapy Versus Repetitive Transcranial Magnetic Stimulation

Two fair MDD-only studies, one Tier 1^58^ and one Tier 2,^59^ found no differences in changes in depressive symptomatology, response, or remission. However, a good-quality Tier 3 MDD/bipolar mix study found a greater change in depressive symptomatology and higher response and remission rates in the ECT group;61,63 a second Tier 3 study rated fair supported these results, showing higher response and remission rates in the ECT group.60

### Electroconvulsive Therapy Versus Electroconvulsive Therapy Plus Repetitive Transcranial Magnetic Stimulation

Two fair studies, one Tier 1 MDD-only64 and one Tier 3 MDD-only,65 found no difference in changes in depressive symptomatology, response, or remission.

## Key Question 1a Nonpharmacologic Interventions—Detailed Analysis of Head-to-Head Comparisons

### Electroconvulsive Therapy Versus Repetitive Magnetic Stimulation

#### Tier 1: Patients With two or More Treatment Failures

One trial comparing ECT with rTMS was identified in Tier 1 (Table 11).

Table 11 Efficacy of ECT versus rTMS: Tiers 1–3

Tier Author, Year Endpoint Current Episode Failure Requirement Quality | Intervention and Sample Size Study Details | Population Characteristics | Change in Depressive Symptoms | Response Remission
Rosa et al., 2006^58^ 2–4 weeks of active treatment (after week 2, rTMS non-responders withdrawn with LOCF) Tier 1: Did not require failure in the current episode Fair | ECT (n = 20) % bilateral NR, mean number of sessions 10 (1.5) rTMS (n = 22) High frequency (10Hz), up to 20 sessions, 2500 pps (slightly outside safety guidelines) Treatment Strategy Switch Definitions Remission Ham-D_17_ ≤ 7 | Mean number of failed antidepressant trials: ECT: NR rTMS: NR Baseline Depression: HAM-D_17_, mean (SD) ECT: 32.1 (5.0)* rTMS: 30.1 (4.7)* *completers analysis ECT: n = 15 rTMS: n = 20 | HAM-D_17_ Change, mean (SD): NR P = 0.86 | HAM-D_17_ Response, n (%) ECT: 6 (20) rTMS: 10 (45) P = 0.35 Remission, n (%) ECT: 3 (15) rTMS: 2 (9) P = 0.65
Grunhaus et al., 2003^59^ 4 weeks for rTMS; ECT was at physician discretion, all reported pts included in analysis Tier 2: Did not require failure in the current episode Fair | ECT (n = 20) 35% bilateral, mean sessions = 10.25 (3.1) rTMS (n = 20) High frequency, 20 sessions Treatment Strategy Switch Definitions Response defined as a decrease ≥ 50% or HAM-D_17_ score ≤ 10 and a GAF rating ≥ 60 Remission defined as HAM-D_17_ ≤ 8 | Number of failed antidepressant trials: % with ≥ 2 failed ECT: 60 rTMS: 65 Baseline Depression: HAM-D_17_, mean (SD) ECT: 25.5 (5.9) rTMS: 24.4 (3.9) | HAM-D_17_ Change, mean (SD) ECT: -12.3 rTMS: -11.1 P = NS | HAM-D_17_ Response, n (%) ECT: 12 (60) rTMS: 11 (55) P = NS Remission, n (%) ECT: 6 (30) rTMS: 6 (30) P = NS
Hansen et al., 2010^60^ 3 weeks, ITT Did not require failure in the current episode Tier 3—referred for ECT Fair | ECT (n = 30) 100% unilateral, 9 sessions rTMS (n = 30) Low frequency, 15 sessions Treatment strategy Augmentation Discontinued antiepileptics prescribed as mood stablizers. Low-dose zopiclone or zopidem if needed for sleep Definitions Partial remission HAM-D_17_ ≤ 12 | Diagnosis Bipolar (%) ECT: 13.3 rTMS: 13.3 Number of failed antidepressant trials: Mean (SD) ECT: NR rTMS: NR Baseline Depression: HAM-D_17_, median (range) ECT: 24 (16-34) rTMS: 24 (14-38) | HAM-D_17_ Change, mean (SD) Reported in graph only | HAM-D_17_ Response, n (%)* ECT: 17 (57) rTMS: 6 (20) Response rate difference = 0.37 (0.14-0.59) Partial Remission, n (%)* ECT: 16 (53) rTMS: 8 (27) Partial Remission rate difference = 0.26 (0.03-0.51)
McLoughlin et al., 2007,^61^ Eranti et al., 2007.^62^ and Knapp et al., 2008^63^ End of treatment (at clinician's discretion for ECT group, 3 weeks in rTMS), mITT Did not require failure in the current episode Tier 3—referred for ECT Good | ECT (n = 22) 82% bilateral, mean session 6.3 (2.5) rTMS (n = 24) High frequency, 15 sessions Treatment strategy Augmentation Definitions Remission defined as ≤ 8 | Diagnosis Bipolar (%) ECT: 9.1 rTMS: 8.3 Number of failed antidepressant trials: Mean (SD) ECT: 2.5 (1.4) rTMS: 2.4 (1.0) Baseline Depression: HAM-D_17_, mean (SD) ECT: 24.8 (5.0) rTMS: 23.9 (7.0) | HAM-D_17_ Change, mean (SD)* ECT: -14.1 rTMS: -5.4 P = 0.017 *only pts with post-baseline assessment ECT: n = 22 rTMS: n = 23 | HAM-D_17_ Response, n (%)* ECT: 13 (59.1) rTMS: 4 (17.4) P = 0.005 Remission, n (%)* ECT: 13 (59.1) rTMS: 4 (17.4) P = 0.005

AD = antidepressant; ECT = electroconvulsive therapy; HAM-D_17_ = 17-item Hamilton Depression Scale; Hz = hertz; LOCF = last observation carried forward; n = number; NR = not reported; P = p-value; pps = pulses per session; pts = patients; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation

##### MDD-Only

One trial directly compared 4 weeks of ECT (n = 20 patients) to high-frequency rTMS (n = 22 patients) (Table 11).58 The mean baseline HAM-D_17_ for treatment completers was 32.1 (SD 5.0) (ECT; n = 15 patients) and 30.1 (standard deviation [SD] 4.7) (rTMS; n = 20 patients), indicating that the groups were severely depressed. ECT was initially unilateral, and it was switched to bilateral if there was no response after 2 weeks; the mean number of treatments was 10. If rTMS patients had not responded after 2 weeks, they exited the study with their last observation carried forward. The treatment strategy was a switch. ITT analyses indicated no difference between the likelihood of response with ECT versus rTMS (20% vs. 45%, P = 0.35), nor was there any difference between the likelihood of remission (15% vs. 9%, P = 0.65).

##### MDD/Bipolar

There were no eligible studies.

#### Tier 2: Patients With one or More Treatment Failures

One trial comparing ECT with rTMS was identified in Tier 2 (Table 11).

##### MDD-Only

One additional study was captured considering Tier 2 (Table 11).59 This trial directly compared up to 4 weeks of ECT (n = 20 patients) with 20 sessions of high-frequency rTMS (n = 20 patients) after patients were switched from antidepressant pharmacotherapy (). Patients were severely depressed (mean HAM-D_17_ for ECT group 25.5 [SD 5.9] and for rTMS group 24.4 [SD 3.9]). For the ECT group, patients began with unilateral treatment but were switched to bilateral treatment if response was limited. Although rTMS treatment totaled 20 sessions, ECT treatment continued until the treating physician assessed that a therapeutic response had been obtained or no further benefit was expected. The authors' analyses accounted for all patients who were randomized. At the end of treatment, ECT and rTMS patients did not differ significantly in either depressive severity (-12.3 vs. -11.1), the response rate (60% vs. 55%), or the remission rate (30% vs. 30%).

##### MDD/Bipolar

There were no eligible studies.

#### Tier 3: Patients With Probable TRD

Two trials comparing ECT with rTMS were identified in Tier 3 (Table 11).60-63

##### MDD-Only

There were no eligible studies.

##### MDD/Bipolar mix

Two studies were identified for Tier 3 (Table 11).60-63 The first study was reported in three articles and was the only good trial involving a head-to-head comparison. Investigators used an augmentation strategy to compare outcomes following 2–3 weeks of ECT (n = 22 patients) versus 3 weeks of rTMS (n = 24) in a group of patients referred for ECT. Although failure of a prior antidepressant treatment was not a selection criterion for the study, the mean number of previous antidepressant failures was approximately 2.5 in each treatment group. The ECT group had 9.1 percent with bipolar disorder (n = 2), and the rTMS groups had 8.3 percent (n = 2) with bipolar disorder. Patients were severely depressed at baseline (mean HAM-D_17_ = 23.9 [SD 7.0] for rTMS and 24.8 [SD 5.0] for ECT). In a modified ITT analysis, ECT patients had better outcomes in all depression domains recorded at the end of treatment. Compared to the rTMS group, those receiving ECT experienced a greater decrease in depressive severity (mean HAM-D_17_ change -14.1 vs. -5.4, P = 0.017) and higher rates of both response and remission (59.1% vs. 17.4%, P = 0.005 for each, as all who responded also remitted).60

A second Tier 3 study comparing ECT with rTMS was rated fair.60 Investigators used a mostly augmentation strategy but required patients to discontinue antiepileptics (when used as mood stabilizers) and benzodiazepines. Patients referred for ECT were randomized to 3 weeks of ECT (n = 30) or rTMS (n = 30). Both groups were severely depressed at baseline (median HAM-D_17_ = 24 [range 16–34] for ECT and 24 [14–38] for rTMS). In an ITT analysis, ECT patients had better outcomes in all depression domains recorded at the end of treatment. Compared to the rTMS group, the ECT group experienced a higher rate of response (57% vs. 20%, rate difference: 0.37 [0.14–0.59]) and partial remission (defined as HAM-D_17_ ≤ 12: 53% vs. 27%, rate difference: 0.26 [0.03–0.51].

#### Tiers 1-3: Combined Results

Although the two Tier 1 studies alone provided limited evidence of no difference between ECT and rTMS, consideration of Tiers 2 and 3 added three studies with varying results: one Tier 2 study showed no difference between ECT and rTMS and two Tier 3 studies favored ECT over rTMS.

In considering studies from all three tiers, then, two fair studies, one Tier 1 and one Tier 2, found no differences between groups in change in depressive severity, response, or remission;58,59 two Tier 3 studies (one good, one fair) found that ECT resulted in greater efficacy across measures.61-63 With only four studies identified for this comparison, it is difficult to assess what study design, participant, or treatment characteristics may have contributed to different results in both intervention efficacy and between-group comparisons.

Although the good study indicating greater efficacy for ECT was identified in Tier 3, the mean number of failed trials (N = 2.4–2.5) indicates substantial overlap with patients included in Tier 1 and Tier 2 studies.61-63 These data were not reported for the second Tier 3 study.60 Baseline characteristics reported in the Tier 2 study also show overlap with Tier 1 populations, with more than 60 percent of participants failing two or more antidepressant treatment trials.59 None of the studies comparing ECT with rTMS required an antidepressant failure in the current episode. Average baseline depression scores indicate severe depression for all study populations. In the two studies allowing bipolar patients, the numbers of patients with this diagnosis were small and patients were equally distributed between treatment groups.60-63

Both studies finding no differences used switch strategies58,59 while the two studies showing greater efficacy for ECT used an augmentation strategy.60-63 Studies employed slightly different intervention methodologies using either high58,59,61-63 or low frequency rTMS60 and unilateral60 or bilateral58,59,61-63 ECT, further complicating comparisons between studies. All studies were 2 to 4 weeks in duration.

### Electroconvulsive Therapy Versus Electroconvulsive Therapy Plus Repetitive Magnetic Stimulation

#### Tier 1: Patients With two or More Treatment Failures

One trial comparing ECT with ECT plus rTMS was identified in Tier 1 (Table 12).64

Table 12 Efficacy of ECT versus ECT plus rTMS: Tiers 1–3

Tier Author, Year Endpoint Current Episode Failure Requirement Quality | Intervention and Sample Size Study Details | Population Characteristics | Change in Depressive Symptoms | Response Remission
Pridmore, 2000^64^ 2 weeks of treatment Did not require failure in the current episode Tier 1 Fair | ECT (n = 11) 100% unilateral, 6 sessions ECT plus rTMS (n = 11) ECT: 100% unilateral (day 1), plus high-frequency rTMS: (days 2-5) Repeated in week 2 Treatment Strategy Primarily augmentation (4 patients not on AD at start). ADs and mood stabilizers continued but other psychotropics discontinued Definitions Remission HAM-D_17_ < 9 | Mean number of failed antidepressant trials: ECT: NR ECT+rTMS: NR Baseline Depression: HAM-D_17_, median ECT: 30 ECT+rTMS: 28 | HAM-D_17_ Change, median ECT: -23 ECT+rTMS G2:-20 P = 0.6 | HAM-D_17_ Remission, n (%) ECT: 6 (54.5) ECT+rTMS G2: 6 (54.5) P = NR
Chistyakov et al., 2005^65^ 3 weeks, all reported patients included Did not require failure in the current episode Tier 3: referred for ECT Fair | ECT plus sham (n = 10) Bilateral ECT (2 days a week) plus sham rTMS (4 days a week) ECT plus rTMS (n = 12) Bilateral ECT (2 days a week) plus low frequency rTMS (4 days a week) Treatment strategy Switch | Mean number of failed antidepressant trials: ECT + sham: NR ECT+rTMS: NR Baseline Depression: HAM-D mean reported in graph only | HAM-D_NR_ Change, mean (SD) ECT+sham: NR ECT+rTMS: NR P > 0.05 | HAM-D_NR_ Response, n (%) Overall: 19 (86) ECT+sham: NR ECT+rTMS: NR P = NS

AD = antidepressants; ECT = electroconvulsive therapy; HAM-D_17_ = 17-item Hamilton Depression Scale; HAM-D_NR_ = Hamilton Depression Scale; n = number; NR = not reported; NS = not significant; P = p-value; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation

##### MDD-Only

One trial directly compared 2 weeks of unilateral ECT (n = 11 patients) to a combination of 1 day of unilateral ECT followed by 4 days of high-frequency rTMS (n = 11 patients).64 Patients were severely depressed at entry (median HAM-D_17_ for ECT group = 30 and for ECT plus rTMS group = 28). For the majority of patients, this trial tested an augmentation strategy. However, four patients (two in each group) were not taking any antidepressant medication at study entry, and patients were allowed to continue any mood stabilizers they were taking (one in each group). ITT analyses showed no clear difference in outcomes between the two groups. Specifically, there was no difference in change in depressive severity (-23 vs. -20, P = 0.6) or remission rates (54.5% vs. 54.5%, P = not reported).

##### MDD/Bipolar

There were no eligible studies.

#### Tier 2: Patients With one or More Failures

There were no eligible studies.

#### Tier 3: Patients With Probable TRD

One trial comparing ECT with ECT plus rTMS was identified in Tier 1 (Table 12).65

##### MDD-Only

Following discontinuation of antidepressant pharmacotherapy (switch strategy), a 3-week study compared 6 sessions of bilateral ECT plus 12 sessions of low frequency rTMS (n = 12) versus 6 sessions of bilateral ECT plus 12 sessions of sham rTMS (n = 10).65 Depressive severity was not reported in text, but figures indicate HAM-D (NR) was above 40 for each group, suggesting very severe depression. The treatment strategy was a switch, and no other psychotropic medications were allowed. All patients were included in the final analysis. There was no clear difference in response rates between ECT plus rTMS versus rTMS alone (data not reported, P = NS).

##### MDD/Bipolar mix

There were no eligible studies.

#### Tier 1-3 Combined Results

Two fair studies found no differences between groups in change in depressive severity, response, or remission.64,65 With only two studies identified for this comparison, it is difficult to assess how study design, participant, or treatment characteristics may have affected treatment efficacy; furthermore, one of the two studies did not report specific data points impeding additional analysis.

Overall, studies appeared similar with the exception of tier. One study fell into Tier 1^64^ and one into Tier 3^65^ with no information provided regarding the average number of antidepressants failed prior to study entry for the Tier 3 study.65 Neither study required a failure in the current episode. All patients were diagnosed with MDD and the average baseline depression scores indicate severe depression for both study populations. Dosing strategies for the combination groups in both studies were similar with patients receiving one to two sessions of ECT and four sessions of rTMS per week. ECT strategies were also similar with patients receiving 2–3 ECT sessions per week. One study used high-frequency rTMS and unilateral ECT64; the other used low frequency rTMS and bilateral ECT.65 Lastly, one study was 2 weeks and the other was 3 weeks.

## Key Question 1a Nonpharmacologic Interventions—Overview of Active Versus Control Comparisons

A total of 31 studies comparing an active nonpharmacologic intervention with a sham or control group were identified (Table 13), providing a total of 4 distinct comparisons: 2 comparing ECT with sham,67,68 24 comparing rTMS with sham,18,69-92 4 comparing psychotherapy with control,93-97 and 1 comparing VNS with a control group.98 The small number of studies within some comparisons (i.e., ECT = two studies, VNS = one study, psychotherapy = four studies) and the clinical heterogeneity between study populations (e.g., severity of depression, previous antidepressant failures) did not allow for indirect comparisons of nonpharmacologic interventions.

Table 13 Number of studies included by comparison and tier for KQ 1a active versus control comparisons

Comparison | Tier | MDD-Only | MDD and Bipolar Disorder
ECT versus sham | Tier 3 (probable) | 1 | 1
rTMS versus sham | Tier 1 (≥ 2 failures) | 10 | 5
rTMS versus sham | Tier 2 (≥ 1 failures) | 4 additional | 2 additional
rTMS versus sham | Tier 3 (probable) | 0 | 3 additional
Psychotherapy versus control | Tier 2 (≥ 1 failures) | 4 additional | 0
VNS versus control | Tier 1 (≥ 2 failures) | 0 | 1 additional

MDD = major depressive disorder; rTMS = repetitive transcranial magnetic stimulation; TAU = treatment as usual; VNS = vagus nerve stimulation

There were no Tier 1 or Tier 2 studies comparing ECT to sham. The 2 studies comparing ECT to sham stimulation were Tier 3 studies that provided no indication of the number of prior antidepressant failures, and both reported treatment completers analyses rather than intention-to-treat. Both studies found better outcomes for the ECT group.67,68

A sufficient number of studies comparing rTMS to sham stimulation allowed for some comparisons across variables. Results for Tier 1 versus Tiers 1–3 combined were consistent and generally consideration of all tiers provided more conservative point estimates with narrower confidence intervals, suggesting that the tier results might be reasonably combined. Results for MDD-only and MDD/bipolar mix populations were in the same direction and of similar magnitude, suggesting that combining results from these two populations was reasonable. A limited number of studies within comparisons restricted analysis and prevented assessment of whether outcomes differed by depressive severity, treatment strategy, or treatment characteristics, or whether failure in the current episode was required.

Four Tier 2 MDD-only studies compared psychotherapy to control.93-97 For the third comparison, one good study reported in two articles95,96 and two fair studies93,97 supported greater outcomes for patients in psychotherapy compared to a control group. A fourth study, also in a Tier 2 MDD-only population, found no differences between groups for decrease in depressive severity or remission.94 Unlike the first three studies,93,95-97 the fourth study used a combination strategy and started all patients on a new antidepressant at the beginning.94

The single study comparing VNS to a control was in a Tier 1 MDD and <20 percent bipolar population.98 This study included patients with a higher level of treatment resistance than other studies comparing interventions in TRD populations. Considering change in HAM-D_24_ and response outcomes only, patients in the VNS groups did not improve significantly more than patients in the control group.

### Strength of Evidence: Tier 1 (TRD)

Strength of evidence assessments were made for three outcomes: change in depressive severity, response rates, and remission rates. A total of 15 different Tier 1 trials compared rTMS versus sham control for at least one of the three outcomes (Table 14). For changes in depressive severity, 14 rTMS versus sham control studies involving 497 participants provide a high degree of evidence that rTMS produces a greater decrease in depressive severity.18,69-73,75-82 Studies that did not report significant differences had small samples. A random effects meta-analysis of 11 Tier 1 studies indicated that rTMS produces a decrease in HAM-D depressive severity of more than 5 points relative to sham control.

Table 14 Strength of Evidence: Efficacy of rTMS versus sham—Tier 1

Comparison | Number of Studies; Subjects | Risk of bias Design/Quality | Consistency | Directness | Precision | Results and Strength of Evidence
Change in depressive severity | 14; 497 | Low RCT 3 good 11 fair | Consistent | Indirect | Precise | rTMS > sham High
Response | 12; 471 | Low RCT 3 good 9 fair | Consistent | Indirect | Precise | rTMS > sham High
Remission | 5; 223 | Low RCT 2 good 3 fair | Consistent | Indirect | Precise | rTMS > sham Moderate

RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation

For response rates, 12 rTMS versus sham control studies involving 471 participants provided a high degree of evidence that rTMS is more likely to produce a response than sham control.18,69-72,74-77,80-82 A random effects meta-analysis of 11 Tier 1 studies shows that patients receiving rTMS are more than three times as likely to achieve a depressive response as patients receiving sham control.

For remission rates, five rTMS versus sham control studies involving 223 patients provided moderate strength of evidence that rTMS produces greater remission rates than rTMS (Table 14).18,74,77,81 A random effects meta-analysis of five Tier 1 studies shows that patients receiving rTMS are more than six times as likely to achieve remission as patients receiving sham control.

In the only other Tier 1 comparison, one good-quality VNS versus sham control study in an MDD/bipolar mix population involving 222 participants provides low evidence that neither a change in depressive severity nor response rates following VNS substantially differ from a sham control (Table 15).98

Table 15 Strength of Evidence: Efficacy of VNS versus Sham—Tier 1

Outcome | Number of Studies; Subjects | Risk of bias Design/Quality | Consistency | Directness | Precision | Results and Strength of Evidence
Change in depressive severity | 1; 222 | RCT Low 1 good | Unknown | Indirect | Precise | No significant difference Low
Response | 1; 222 | RCT Low 1 good | Unknown | Indirect | Precise | No significant difference Low
Remission | 0; 0 | — | — | — | — | —

RCT = randomized controlled trial; VNS = vagus nerve stimulation

## Key Question 1a Efficacy or Effectiveness of Nonpharmacologic Interventions for Acute Phase Treatment—Key Points of Active Versus Control Comparisons

Active versus control comparisons were also limited, and the small number of studies within comparisons prevented an indirect meta-analytic synthesis. Comparisons of an active nonpharmacologic intervention compared to a sham or control group were available for 4 distinct comparisons: 2 comparing ECT with sham,67,68 24 comparing rTMS with sham,18,69-92 4 comparing psychotherapy with control,93-97 and 1 comparing VNS with a control group.98 The small number of studies within some comparisons (i.e., ECT = two studies, VNS = one study, psychotherapy = four studies) and the clinical heterogeneity between study populations (e.g., severity of depression, previous antidepressant failures) did not allow for indirect comparisons of nonpharmacologic interventions.

### Electroconvulsive Therapy Versus Sham

We identified no ECT versus sham studies conducted in a Tier 1 population. Two Tier 3 studies comparing ECT with sham stimulation were identified.67,68 These two studies provided no indication of the number of prior antidepressant failures, and both reported treatment completers analyses rather than intention-to-treat. Both studies found greater outcomes for the ECT group.

### Repetitive Magnetic Stimulation Versus Sham

For Tier 1, 10 MDD-only69-78 and 5 MDD/bipolar mix studies were identified.18,79-82 Three studies were deemed good quality,18,77,80 and the remaining studies were assessed as fair. Though some studies did not report tests of statistical significance or had very small sample sizes, evidence generally supported the benefit of rTMS over sham for a decrease in depressive symptomatology and a greater likelihood of response and remission. Results from MDD-only and from MDD/bipolar mix studies were in the same direction and of similar magnitude, and results from combining these two populations did not substantially differ from MDD-only, suggesting that combining these two populations was reasonable. Meta-analyses in TRD (Tier 1) involving both MDD-only and MDD/bipolar mix populations indicated benefit for rTMS over sham. TRD patients treated with rTMS had significantly greater decreases in depressive symptomatology (decrease in HAM-D -5.74, 95% confidence interval [CI], -7.79 to -3.68). rTMS patients were also over 3 times as likely to respond (pooled relative risk for response 3.34, 95% CI, 1.92-5.82, which translates to a number needed to treat (NNT) of 5 [95% CI, 3-10]), and over 6 times as likely to remit (pooled relative risk for remission 6.12, 95% CI, 1.89-19.80), with a NNT of 4 (95% CI, 2-20).

Consideration of all tiers together for the combined MDD and MDD/bipolar mix populations provided results consistent with those from Tier 1 alone combined but with more conservative point estimates and narrower confidence intervals. The weighted mean difference in HAM-D depressive severity was -5.92 (95% CI, -8.15 to -3.70). Because sample sizes of individual studies were small and responses to placebo varied in the small control groups, the heterogeneity was high (I^2^ = 80%) and our estimates are uncertain with respect to the magnitude of changes on the HAM-D. The pooled relative risk indicated that patients receiving rTMS were more than twice as likely to respond as those receiving placebo (pooled relative risk 2.68, 95% CI, 1.52-4.70), which translates into an NNT of 5 (95% CI, 4-9). Remission rates also favored rTMS. The pooled relative risk for remission was 3.73 (95% CI, 1.23-11.30), which translates to a NNT of 6 (95% CI, 3-50).

This finding of the above clinical outcomes from Tiers 1, 2, and 3 reflecting what was found with Tier 1 alone held whether the population included was MDD-only, or MDD/bipolar mix, respectively. Findings addressing the remaining key PICOTS elements were limited. Three quarters of the Tier 1 studies used an augmentation strategy18,69-75,79-81 while others (all MDD-only) used a switch (n = 1)76 or a mixed strategy (n = 2).77,78 There was no clear difference in outcome as a function of strategy, but the limited number of comparisons prevented a firm conclusion. The consideration of additional tiers of evidence did not affect this finding.

For the few Tier 1 studies, we were unable to detect clear differences by treatment characteristics (i.e., pharmacotherapy strategy, rTMS frequency, or treatment duration) through qualitative analysis due to other potentially confounding variables resulting from study design or participant characteristics. The consideration of additional tiers of evidence did not affect this finding.

For Tier 1, 1 study did not report baseline depressive severity,79 1 study focused on patients with moderate disease severity,72 and the remaining 10 studies were on patients with severe depression. With little variation by depressive severity, we were unable to detect any differences by this variable. The consideration of additional tiers of evidence did not affect this finding.

Only three studies required a failure in the current episode, two in MDD-only70,72 and one in MDD/bipolar mix,79 with no differences in outcomes apparent, but the small number of studies prevented a more formal analysis. The consideration of additional tiers of evidence did not affect this finding.

Finally, studies used a range of rTMS and sham stimulation parameters, treatment durations, and pharmacotherapy options, thereby confounding any analysis by treatment characteristics.

### Psychotherapy Versus Control

Four Tier 2 studies, all involving a form of cognitive behavioral therapy, compared psychotherapy versus control. One good study reported in two articles,95,96 and two fair studies93,97 supported better outcomes for patients in psychotherapy compared with a control group. A fourth study, also in a Tier 2 MDD-only population, found no differences between groups for decrease in depressive severity or remission.94 Unlike the first three studies,93,95-97 the fourth study used a combination strategy and started all patients on a new antidepressant at the beginning of the strategy.94

### Vagus Nerve Stimulation Versus Sham

We identified only one study comparing VNS to sham, conducted in a Tier 1 MDD/bipolar mix population.98 The majority of measures used by this study found no difference between VNS and sham on changes in depressive severity or rates of response and remission. Since only a single study was identified for this comparison, further assessment by key variables was not possible.

## Key Question 1a Efficacy or Effectiveness of Nonpharmacologic Interventions for Acute Phase Treatment—Detailed Analysis of Active Versus Control Comparisons

### Electroconvulsive Therapy Versus Sham

We identified two Tier 3 studies that compared ECT versus sham stimulation. Both studies comparing ECT to sham stimulation were in Tier 3 populations and were conducted in the early 1980s, limiting comparability to other studies in this report due to difference in antidepressant availability and study populations (e.g., no documented antidepressant failures).

#### Tier 1: Patients With two or More Treatment Failures

No study comparing ECT with sham in a Tier 1 population was identified.

#### Tier 2: Patients With one or More Treatment Failures

No study comparing ECT with sham in a Tier 2 population was identified.

#### Tier 3: Patients With Probable TRD

Two trials comparing ECT with sham stimulation were identified in Tier 3 (Table 16).

Table 16 Efficacy of ECT versus sham: Tier 3

Author, Year Endpoint Current Episode Failure Requirement Quality | Intervention and Sample Size Study Details | Population Characteristics | Change in Depressive Symptoms | Response Remission
West, 1981^67^ 3 weeks, completers Did not require failure in the current episode Tier 3: referred for ECT Fair | ECT (n = 13) Bilateral, 6 sessions Sham (n = 12) Treatment strategy Combination - unclear if patients taking an AD at baseline; 50 mg/d Amitriptyline during the trial | Mean number of failed antidepressant trials: ECT: NR Sham: NR Baseline Depression BDI, mean (SD) ECT: 26.6 (2.8) Sham: 24.1 (3.5) | BDI Change, mean (SD) ECT: -15.8 Sham: -1.9 P < 0.002 Completers ECT: N=11 Sham N=11 | BDI Response NR Remission NR
Johnstone et al., 1980^68^ 4 weeks, completers Did not require failure in the current episode Tier 3: referred for ECT Fair | ECT (n = 35) Bilateral, 8 sessions Sham (n = 35) Treatment strategy Switch - unclear if patients taking an AD at baseline. No AD allowed during the trial | Previous manic episodes: Overall: 10% Mean number of failed antidepressant trials: ECT: NR Sham: NR Baseline Depression HAM-D_17_, mean (SD) Reported in graph only | HAM-D_17_ Change, mean (SD) Reported in graph only *ECT versus sham P < 0.01 Completers ECT N = 31 Sham N = 31 | HAM-D_17_ Response NR Remission NR

ECT = electroconvulsive therapy; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation

##### MDD-Only

One study in a population with “primary depressive illness” referred for ECT compared ECT (N = 13) with sham stimulation (N = 12).67 Participants in this study had moderate depression at study entry (mean BDI, ECT 26.6 [2.8] and sham 24.1[3.5]). It is unclear what proportion of patients was on an antidepressant at study entry or had an antidepressant failure in the past. All patients were prescribed amitriptyline during the trial. Based on a completers analysis, the ECT group had a larger mean decrease in depressive severity compared to the sham group (mean change in BDI, ECT, -15.8 versus sham: -1.9, P < 0.002).

##### MDD/Bipolar

One study in a population with “severe endogenous depression” referred for ECT compared ECT (N = 35) with sham stimulation (N = 35).68 Participants in the study appear to have severe depression but these data are only reported in a graph. It is unclear what proportion of patients was on an antidepressant at study entry or had an antidepressant failure in the past. During the trial, patients were not prescribed an antidepressant medication. Based on a completers analysis, the ECT groups had a greater decrease in depressive severity compared with the sham group (P < 0.01).

#### Tiers 1-3 Combined

Only Tier 3 studies were identified with results reported above. Given the limited data, we did not perform any quantitative syntheses.

### Repetitive Magnetic Stimulation Versus Sham

Considering all tiers of evidence, 24 studies provided an rTMS versus sham comparison.18,69-92Fifteen were Tier 1 studies,18,69-82 six were Tier 2 studies,83-89 and three were Tier 3 studies.90-92 Fifteen involved an MDD-only population69-78 and nine had an MDD/bipolar mixture (< 20% with bipolar disorder).83-87

#### Tier 1: Patients With two or More Treatment Failures

Fifteen Tier 1 trials comparing rTMS with sham were identified in Tier 1.^18,69-82^

##### MDD-Only

Of the 10 Tier 1 MDD-only studies identified,69-78,99 only 1 trial was good quality.77,99 Seven of these studies tested rTMS as an augmentation strategy (Table 17).69-75 A 2-week augmentation study compared high-frequency rTMS (n = 12 patients) to sham rTMS treatment (n = 9 patients).69 At entry, patients in the two groups were severely depressed (mean HAM-D_25_ item scores were 34.4 in the rTMS groups and 31.7 in the control group). Analysis was modified ITT. Patients in the rTMS group had a mean change in HAM-D_25_ severity of -11.75 versus -6.22 in the sham stimulation group (P = ns); the small sample size likely limited the power to detect a difference. Using the study's definition of response (> 30% in HAM-D_25_ item), 58.3 percent of rTMS patients responded compared to 22.2 percent of the sham stimulation group (P = not reported). Using a more standard definition of response as 50 percent or greater decrease (which we were able to calculate from study information), 22.2 percent of rTMS patients responded.

Table 17 Efficacy of rTMS versus Sham: Tier 1, MDD, augmentation strategies

Author, Year Endpoint Current Episode Failure Requirement Quality | Intervention and Sample Size Study Details | Population Characteristics | Change in Depressive Symptoms | Response Remission
Boutros et al., 2002^69^ 2 weeks Did not require failure in the current episode Fair | rTMS (n = 12) High frequency, 10 sessions Sham (n = 9) Treatment strategy Augmentation Definitions Response1 definition: >30% decrease in HAM-D_25_ Response2 definition: ≥50% decrease in HAM-D_25_ **calculated from table | Mean number of failed antidepressant trials: rTMS: NR Sham: NR Baseline Depression HAM-D_25_, mean (SD) rTMS: 34.4 (10.1) Sham: 31.7 (4.9) | HAM-D_25_ Change, mean (SD) rTMS: -11.75 Sham: -6.22 P = NS | HAM-D_25_ Response1, n (%) rTMS: 7 (58.3) Sham: 2 (22.2) P = NR Response2, n (%)** rTMS: 3 (25.0) Sham: 2 (22.2) P = NR
Garcia-Toro et al., 2001^70^ 2 weeks, completers analysis Required failure in the current episode Fair | rTMS (n = 20) High frequency, 10 sessions Sham (n = 20) Treatment Strategy Augmentation | Mean number of failed antidepressant trials: rTMS: NR Sham: NR Baseline Depression HAM-D_21_, mean (SD) rTMS: 27.11 (6.65) Sham: 25.6 (4.92) | HAM-D_21_* Change, mean (SD) rTMS: -7.05 (5.66) Sham: -1.77 (3.78) P = 0.003 *all results based on completers (rTMS: n = 17, Sham: n = 18) | HAM-D_21_* Response, n (%) rTMS: 5 (25) Sham: 1 (5) P = NR
Garcia-Toro et al., 2006^71^ 2 weeks, all reported paticipants included in analysis Did not require failure in the current episode Fair | rTMS-1 (n = 10) High frequency plus low frequency, 10 sessions rTMS-2 (n = 10) Same as above, but with individually assessed location Sham rTMS (n = 10) Double winged coil angled at 45 degrees Treatment strategy Augmentation | Mean number of failed antidepressant trials: rTMS: NR Sham: NR Baseline Depression HAM-D_21_, mean (SD) rTMS-1: 27.30 (4.97) rTMS-2: 25.00 (4.14) Sham: 25.10 (7.28) | HAM-D_21_ Change, mean (SD) rTMS-1: -7.2 rTMS-2: -6.9 Sham: -1.5 rTMS-1 plus rTMS-2 (-7.05) versus Sham, P = 0.048 | HAM-D_21_ Response, n (%) rTMS-1: 2 (20) rTMS-2: 2 (20) Sham: 0 (0) P = NR
Kauffmann et al., 2004^72^ 2 weeks Did not require failure in the current episode Fair | rTMS (n = 7) Low frequency, 10 sessions Sham (n = 5) Treatment Strategy Augmentation, pts encouraged to discontinue mood stablizers Definitions Remission: HAM-D_21_ < 10 | Mean number of failed antidepressant trials: rTMS: NR Sham: NR Baseline Depression HAM-D_21_, mean (SD) rTMS: 21.86 (2.31) Sham: 18.20 (2.20) | HAM-D_21_ Change, mean (SD) rTMS: -10.57 Sham: -6.31 P = NS | HAM-D_21_ Response, n (%) rTMS: 4 (57) Sham: 2 (40) P = NR Remission, n (%) rTMS: 4 (57) Sham: 1 (20) P = NR
Padberg et al., 1999^73^ 1 week Required failure in the current episode Fair | rTMS (n = 6) High frequency, 5 sessions Low-left rTMS (n = 6) 0.3 Hz, Left-DLPFC, 5 sessions Sham rTMS (n = 6) Treatment strategy Augmentation, 16.7% not on medication at study entry | Mean number of failed antidepressant trials (current episode): rTMS: 4.0 (2.2) Low-left rTMS: 3.2 (0.8) Sham: 3.2 (1.2) Baseline Depression HAM-D_21_, mean (SD) High rTMS: 30.2 (9.5) Low-left rTMS: 26.7 (9.4) Sham: 22.2 (8.8) | HAM-D_21_ Change, mean (SD) High rTMS: -1.7 Low-left rTMS: -5.2 Sham: -1.3 P = NS | HAM-D_21_ Response: NR Remission: NR
Pallanti et al., 2010^74^ 3 weeks Did not require failure in the current episode Fair | Low plus High rTMS (n = 20) Low then high frequency, 15 sessions rTMS (n = 20) Low frequency, 15 sessions Sham (n = 20) Treatment strategy Augmentation Definitions Remission HAM-D_17_ ≤ 8 | Mean number of failed antidepressant trials: In lifetime rTMS1: 5.90 (1.48) rTMS2: 6.50 (1.48) Sham: 5.95 (1.67) Baseline Depression HAM-D_17_, mean (SD) rTMS1: 28.75 (6.01) rTMS2:27.95 (5.89) Sham: 29.05 (3.54) | HAM-D_17_ Change, mean (SD) rTMS1: NR rTMS2:NR Sham: NR | HAM-D_17_ Response, n (%) rTMS1: 4 (20%) rTMS2: 7 (35%) Sham: 2 (10%) P = NR NNT (95% CI) rTMS1 vs Sham 10.00 (3.13 to - 8.39) rTMS2 vs Sham 4.00 (2.01 to 328.11) Remission, n (%) rTMS1: 2 (10%) rTMS2: 6 (30%) Sham: 1 (5%) P = 0.064 NNT (95% CI) rTMS1 versus sham 20.00 (4.71 to -8.89) rTMS2 vs sham 4.00 (2.12 to 36.23)
Zheng et al., 2010^75^ 4 weeks Did not require failure in the current episode Fair | rTMS (n = 19) High frequency, 20 sessions Sham (n = 15) Treatment strategy Augmentation – all patients taking escitalopram 2+ weeks before trial | Mean number of failed antidepressant trials: NR Baseline Depression HAM-D_17_, mean (SD) rTMS: 24.6 (2.9) Sham: 24.6 (2.8) | HAM-D_17_ Change, mean (SD) rTMS: -11.1 Sham: -1.7 P = NR | HAM-D_17_ Response, n (%) rTMS: 12 (63.2) Sham: 1 (6.7) P = NR Remission NR

DLPFC = dorsolateral prefrontal cortex; HAM-D_17_ = 17-Item Hamilton Depression Scale; HAM-D_21_ = 21-Item Hamilton Depression Scale; HAM-D_25_ = 25-Item Hamilton Depression Scale; Hz = hertz; n = number; NR = not reported; NS = not significant; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation

The largest augmentation study was a 2-week trial that compared high-frequency rTMS (n = 20 patients) to a sham control (n = 20 patients).70 Participants' depression was severe (mean HAM-D_21_ in rTMS group = 27.1, and 25.6 in control). In an analysis of treatment completers, rTMS patients had a greater decrease in depressive severity (-7.05 vs. -1.77, P = 0.003). Including all participants, rTMS patients had a greater likelihood of response (25% vs. 5, P = NR) compared to control patients.

Another 2-week study testing augmentation compared 2 active rTMS treatments (n = 10 patients each) with each other and with 10 sessions of sham stimulation (n = 10 patients).71 Enrolled patients were severely depressed (mean HAM-D_21_ item scores for each group between 25 and 27.3). The three groups did not appear to differ by decrease in depressive severity. However, the two active groups combined did have a greater 2-week decrease in depressive severity than the sham control group (-7.05 vs. -1.5, P = 0.048). Also, 2 of 10 patients in each of the active groups responded at 2 weeks, compared to no patients in the control group (P = NR).

A small trial compared outcomes at 2 weeks after 10 sessions of low-frequency rTMS treatment (n = 7 patients) with sham rTMS treatment (n = 5 patients).72 The groups had moderate depressive severity (HAM-D_21_, 21.86 for rTMS, 18.2 for control). Although mostly an augmentation study, patients were advised to discontinue benzodiazepines and mood stabilizers. ITT analyses showed that patients receiving rTMS had a 10.57 decrease in HAM-D_21_ compared to a 6.31 decrease for the sham stimulation group (P = NS). Response rates did not differ between the two groups (57% vs. 40%, P = NS). Investigators in this study also reported (57% vs. 20%, P = NS) the percentage of participants scoring less than 10 on the Hamilton Depression Scale. Again, small sample sizes may have limited the power to detect differences.

An additional small trial compared outcomes after 1 week of treatment with high-frequency rTMS (n = 6 patients), low-frequency rTMS to the left dorsolateral prefrontal cortex (n = 6 patients), or sham rTMS stimulation (n = 6 patients).73 One treatment failure needed to have occurred in the current episode. Enrolled patients were moderately to severely depressed (mean HAM-D_21_ score 30.2, 26.7, and 22.2 for high-frequency, low-frequency, and control groups, respectively). Patients receiving low-frequency rTMS had a significant decrease in depressive severity relative to baseline (mean HAM-D_21_ change -1.7 for high frequency, -5.2 for low frequency to the left dorsolateral prefrontal cortex, and - 1.3 for sham stimulation), but there was no difference in treatment effect between groups in this small study.

Another 3-week augmentation trial compared bilateral high- and low-frequency rTMS (n = 20), unilateral low-frequency rTMS (n = 20), and sham rTMS stimulation (n = 20).74 Patients in this study were severely depressed (HAM-D_17_ mean [SD] bilateral rTMS 28.75 [6.01] unilateral rTMS 27.95 [5.89] sham 29.05 [3.54]) and had a high number of previous antidepressant treatment failures (mean [SD] bilateral rTMS 5.90 [1.48] unilateral rTMS 6.50 [1.48] sham 5.95 [1.67]). In an ITT analysis, patients in the unilateral low-frequency rTMS but not the bilateral rTMS group were more likely to respond (NNT [95% CI] unilateral rTMS versus sham 4.00 [2.01-328.11] bilateral rTMS versus sham 10.00 [3.13 to -8.39]) and remit (NNT [95% CI] unilateral rTMS versus sham 4.00 [2.12-36.23]) bilateral rTMS versus sham 20.00 [4.71 to -8.89]) from treatment compared to sham stimulation.

The last augmentation study, a 4-week trial, compared high-frequency rTMS (n = 19) to sham rTMS treatment (n = 15).75 At baseline, participants were severely depressed (HAM-D_17_ mean [SD] rTMS 24.6 [2.9] sham 24.6 [2.8]) and had been taking escitalopram for at least 2 weeks. In an ITT analysis, participants in the rTMS group had a greater decrease in depressive severity (rTMS -11.1 versus sham -1.7, P = NR) and a higher response rate (rTMS 63.2% sham 6.7%, P = 0.001).

Of the remaining three studies identified, one tested a switch strategy and two used a mixed strategy (Table 18). The single switch study tested was a small 2-week trial that compared high-frequency rTMS (n = 7 patients) to sham rTMS stimulation (n = 8 patients).76 Patients were severely depressed (mean HAM-D_17_ for the two groups was between 20 and 23). At 2-week followup, ITT analysis indicated that the decrease in depressive severity did not differ between the two groups (-8.1 for rTMS, -5.5 for sham, P = NS). Similarly, the rate of response did not appear to differ (28.6% vs. 12.5%, P = NR).

Table 18 Efficacy of rTMS versus sham: Tier 1, MDD, mixed and switch strategies

Strategy Author, Year Endpoint Current Episode Failure Requirement Quality | Intervention and Sample Size Study Details | Population Characteristics | | Change in Depressive Symptoms | Response Remission
Holtzheimer et al., 2004^76^ 2 weeks Did not require failure in the current episode Fair | rTMS (n = 7) High frequency rTMS, 10 sessions Sham rTMS (n = 8) Treatment strategy Switch | Mean number of failed antidepressant trials: rTMS: NR Sham: NR Baseline Depression HAM-D_17_, mean (SD) rTMS: 22.7 (5.3) Sham: 20.8 (6.3) | | HAM-D_17_ Change, mean (SD) rTMS: -8.1 Sham: -5.5 P = NS | HAM-D_17_ Response, n (%) rTMS: 2 (28.6) Sham: 1 (14.3) P = NR
Avery et al., 2006^77^ Patients treated over 4 weeks and primary endpoint 1 week after final txt Did not require failure in the current episode Good | rTMS (n = 35) High frequency, 15 sessions over 4 weeks Sham (n = 33) Treatment strategy Mixed-within group differences 31% of rTMS group and 27% of control group continued taking medications Definitions Remission definition: HAM-D_17_ < 10 | Mean number of failed antidepressant trials: rTMS: 3.2 (2.44) Sham: 3.3 (1.72) Mean number of failed antidepressant trials (current episode): rTMS: 1.46 (0.78) Sham: 1.48 (0.67) Baseline Depression HAM-D_17_, mean (SD) rTMS: 23.5 (3.9) Sham: 23.5 (2.9) | | HAM-D_17_ Change, mean (SD) rTMS: -7.8 (7.8) Sham: -3.7 (6.3) P = 0.002 | HAM-D_17_ Response, n (%) rTMS: 11 (31.4) Sham: 2 (6.1) P = 0.008 Remission, n rTMS: 7 (20.0) Sham: 1 (3.0) P = 0.033
Pascual-Leone et al., 1996^78^ Crossover trial, 1 week Did not require failure in the current episode Fair | rTMS (n = 17) High frequency, 5 sessions Sham (n = 17) Combined data from 4 control stimulations Treatment strategy Mixed—within group differences and combination (All pts in both groups given 30 mg/d nimodipine) | Mean number of failed antidepressant trials: rTMS: NR Sham: NR Baseline Depression HAM-D_21_, mean: NR | HAM-D_21_ Change, mean: TMS: NR Sham: NR P < 0.0005 | | HAM-D_21_ Response: NR Remission: NR

DLPFC = dorsolateral prefrontal cortex; HAM-D_17_ = 17-item Hamilton Depression Scale; HAM-D_21_ = 21-item Hamilton Depression Scale; HAM-D_25_ = 25-item Hamilton Depression Scale; Hz = hertz; mg/d = milligram per day; MT = motor threshold; n = number; NR = not reported; NS = not significant; P = p-value; pts = patients; pps = pulses per session; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation; txt(s) = treatment(s); vs. = versus

Two studies tested a mixed strategy.77,78 One of these trials was a good-quality 4-week study that compared 15 sessions of left-sided high-frequency rTMS (n = 35 patients) to control treatment (n = 33 patients), and was the only one to report remission rates in this tier.77,99 Groups enrolled were in general severely depressed (mean HAM-D_17_ score 23.5). This mixed strategy was primarily a switch, although a substantial percentage of patients continued antidepressants (31% of rTMS group, 27% of control group) and benzodiazepines (26% and 24%, respectively). Outcomes were measured 1 week after completing the 4-week treatment, and all ITT analyses favored the rTMS group. Compared to controls, the rTMS group had a greater decrease in depressive severity (-7.8 vs. -3.7, P = 0.002), a greater response rate (31.4% vs. 6.1%, P = 0.008), and a greater remission rate (20.0% vs. 3.0%, P = 0.033).

One small mixed study used a crossover design to compare 17 TRD patients with psychotic symptoms randomized to receive different orderings of 1 high-frequency rTMS intervention and 4 different sham rTMS interventions over a 5-week period.78 Patients had at least three episodes of depression that had been resistant to multiple medications. Baseline depressive severity was not reported. Though patients attempted to discontinue their antidepressant medication, many were unable to do so, making this strategy mixed (within group differences). All patients received nimodipine (which appears to have mood stabilizing effects) as a combination treatment with both the active rTMS and control interventions. Results suggested that the active rTMS produced greater improvement in HAM-D_21_ scores than comparison groups (P < 0.0005).

##### Meta-Analytic Synthesis of Tier 1 MDD-Only

Meta-analyses supported the benefit of rTMS over sham control. The weighted mean difference in HAM-D depressive severity was -5.18 (95% CI, -6.79 to -3.58) (Figure 5).

Figure 5 Mean difference meta-analysis of change in depresssive severity comparing rTMS with sham: Tier 1, MDD

Figure 5 shows the study statistics and forest plots for the random effects meta-analysis of the mean difference between rTMS and sham groups for decreases in depressive severity (on the HAM-D) in a Tier 1 MDD only population. Avery et al., 2006 reports a difference in means equal to -4.10 (95%CI, -7.48 to -0.72). Boutros et al., 2002 reports a difference in means equal to -5.60 (95%CI, -11.00 to -0.20). Garcia-Toro et al., 2001 reports a difference in means equal to -5.30 (95%CI, -8.30 to -2.30). Garcia-Toro et al.,2006 reports a difference in means equal to -5.60 (95%CI, -10.52 to -0.68). Holtzheimer et al., 2004 reports a difference in means equal to -2.60 (95%CI, -8.98 to 3.78). Kauffmann et al., 2004 reports a difference in means equal to -4.30 (95%CI, -11.77 to 3.17). Padberg et al., 1999 reports a difference in means equal to -0.40 (95%CI, -7.59 to 6.79). Zheng et al., 2010 reports a difference in means equal to -9.40 (95%CI, -13.77 to -5.03). Overall, the meta-analysis showed a difference in means equal to -5.18 (95%CI -6.79 to -3.58, I2 = 0%).

The pooled relative risk indicated that patients receiveing rTMS were more than 2½ likely to have a treatment reponse as those receiving sham treatment (pooled relative risk = 2.82, 95% CI, 1.57-509) (Figure 6), which translates to a NNT of 5 (95% CI, 3 to 10).

Figure 6 Relative risk meta-analysis or reponse rates comparing rTMS with sham: Tier 1, MDD

Figure 6 shows the study statistics and forest plots for the random effects meta-analysis of the relative risk for response in rTMS compared to sham in a Tier 1 MDD only population. Avery et al., 2006 reports a relative risk for response of 5.19 (95%CI, 1.24 to 21.66). Boutros et al., 2002 reports a relative risk for response of 1.25 (95%CI, 0.26 to 6.07). Garcia-Toro et al., 2001 reports a relative risk for response of 5.00 (95%CI, 0.64 to 39.06). Garcia-Toro et al., 2006 reports a relative risk for response of 4.61 (95%CI, 0.27 to 77.76). Holtzheimer et al., 2004 reports a relative risk for response of 2.29 (95%CI, 0.26 to 20.13). Kauffmann et al., 2004 reports a relative risk for response of 1.43 (95%CI, 0.41 to 4.99). Pallanti et al., 2010 reports a relative risk for response of 2.75 (95%CI, 0.67 to 11.24). Zheng et al., 2010 reports a relative risk for response of 9.47 (95%CI, 1.38 to 64.90). Overall, the meta-analysis showed a relative risk for response of 2.82 (95%CI 1.57 to 5.09, I2 = 0%).

The pooled relative risk indicated that patients receiving rTMS were more than four times as likely to achieve remission as patients receiving sham stimulation (pooled relative risk = 4.12, 95% CI, 1.32-12.84) (Figure 7). This translates to an NNT of 6 (95% CI, 4-14).

Figure 7 Relative risk meta-analysis of remission rates comparing rTMS with Sham: Tier 1, MDD

Figure 7 shows the study statistics and forest plots for the random effects meta-analysis of the relative risk for remission in rTMS compared to sham in a Tier 1 MDD only population. Avery et al., 2006 reports a relative risk for remission of 6.60 (95%CI, .86 to 50.79). Kauffmann et al., 2004 reports a relative risk for remission of 2.86 (95%CI, 0.44 to 18.48). Pallanti et al., 2010 reports a relative risk for response of 4.00 (95%CI, 0.54 to 29.80). Overall, the meta-analysis showed a relative risk for remission of 4.12 (95%CI 1.32 to 12.84, I2 = 0%).

##### MDD/Bipolar

For rTMS versus sham, five Tier 1 studies involving MDD/bipolar mix population, all using augmentations strategies, were identified18.^79-82^ These studies are summarized in Table 19 with detailed descripations provided in the evidence tables (Appendix E).

Table 19 Efficacy of rTMS versus sham: Tier 1, MDD and ≤ 20 percent bipolar disorder, augmentation strategies

Author, Year Endpoint Current Episode Failure Requirement Quality | Intervention and Sample Size Study Details | Population Characteristics | Change in Depressive Symptoms | Response Remission
Bocchio-Chiavetto et al., 2008^79^ Crossover, 1 week, all reported patients included in the analysis Required failure in the current episode Fair | rTMS (n = 36) Low Frequency rTMS (n = 18) 5 sessions OR, High Frequency rTMS (n = 18) 5 sessions Sham (n = 15) Treatment strategy Augmentation | Diagnosis Bipolar (%) Overall: 13.9 Mean number of failed antidepressant trials: Overall: 2.89 Baseline Depression HAM-D_21_, mean (SD) rTMS: 23.19 (5.12) Sham: 24.53 (4.79) | HAM-D_21_ Change, mean (SD) rTMS: -5.69 Sham: -3.40 P = NR | HAM-D_21_ Response, n (%) NR Remission, n (%) NR
Fitzgerald et al., 2003^80^ 2 weeks Did not require failure in the current episode Good | High rTMS (n = 20) High frequency, 10 sessions Low rTMS (n = 20) Low frequency, 10 sessions Sham (n = 20) Treatment strategy Augmentation Definitions Response1 definition: >20% decrease in MADRS score Response2 definition: ≥50% decrease in MADRS | Diagnosis Bipolar (%) High rTMS: 5 Low rTMS: 5 Sham: 20 Mean number of failed antidepressant trials: Overall: 5.68 (3.40) Baseline Depression MADRS, mean (SD) High rTMS: 36.05 (7.55) Low rTMS G2: 37.70 (8.36) Sham: 35.75 (8.14) | MADRS Change, mean (SD) High rTMS: - 5.25 Low rTMS G2: -5.5 Sham: -0.35 High rTMS versus sham, low rTMS versus sham, P < 0.005 | MADRS Response1, n (%) High rTMS: 8 (40) Low rTMS: 7 (35) Sham: 2 (10) P = 0.07 Response2, n (%) High rTMS: 0 (0) Low rTMS: 1 (5) Sham: 0 (0) P = NR
Fitzgerald et al., 2006^18^ 6 weeks of txt (after 2 weeks, patients with < 20% decrease in score exited with LOCF) Did not require failure in current episode Good | High plus Low rTMS (n = 25) High frequency rTMS up to 30 sessions plus low frequency rTMS up to 30 sessions Sham (n = 25) Treatment strategy Augmentation, 23% not taking any medication at start of study Definitions Remission definition: HAM-D_17_ < 8 | Diagnosis Bipolar (%) rTMS: 16 Sham: 16 Mean number of failed antidepressant trials: rTMS: 5.6 (3.1) Sham: 6.2 (3.0) Baseline Depression HAM-D_17_, mean (SD) rTMS: 22.5 (7.4) Sham: 19.8 (4.4) | HAM-D_17_ rTMS: -10.2 Sham: 1.1 P < 0.001 | HAM-D_17_ Response, n (%) rTMS: 13 (52) Sham: 2 (8) P = 0.001 Remission (%) rTMS: 10 (40) Sham: 0 (0) P = 0.001
Su et al., 2005^81^ 2 weeks, completers analysis Did not require failure in the current episode Fair | 20 Hz rTMS (n = 11) High frequency (20 Hz), 10 sessions 5 Hz rTMS (n = 11) High frequency (5 Hz),10 sessions Sham (n = 11) Treatment strategy Augmentation Definitions Remission defined as HAM-D_21_ < 8 | Diagnosis Bipolar (%) 20 Hz rTMS: 10 5 Hz rTMS G2: 20 Sham G3: 20 Mean number of failed antidepressant trials: 20 Hz rTMS: NR 5 Hz rTMS G2: NR Sham G3: NR Baseline Depression HAM-D_21_, mean (SD) 20 Hz rTMS: 23.2 (7.5) 5 Hz rTMS: 26.5 (5.2) Sham: 22.7 (4.7) | HAM-D_21_* Change, mean (SD) 20 Hz rTMS: - 13.4 (4.9) 5 Hz rTMS: - 14.2 (6.0) Sham: -3.7 (9.3) P < 0.01 *n analyzed: n = 10 in each group | HAM-D_21_* Response, n (%) 20 Hz rTMS: 6 (60) 5 Hz rTMS: 6 (60) Sham: 1 (10) P = 0.01 Remission, n (%) 20 Hz rTMS: 5 (50) 5 Hz rTMS: 5 (50) Sham: 0 (0) P = NR
Triggs et al., 2010^82^ 2 weeks Did not require failure in the current episode Fair | High rTMS (n = 18) High frequency, 10 sessions High right rTMS (n = 16) High frequency to the right prefrontal cortex, 10 sessions Sham left (n = 7) Sham right (n = 7) Treatment strategy Augmentation NOTE: Patients in all groups also received a social support intervention | Baseline Depression HAM-D_24_, mean (SD) rTMS1: 28.2 (6.0) rTMS2: 27.2 (4.8) Sham1: 27.7(3.5) Sham2: 27.3 (2.7) Diagnosis Bipolar (%) rTMS1: 0 rTMS1: 12.5 Sham1: 0 Sham2: 0 Mean failed antidepressant trials NR | HAM-D_24_ Change, mean (SD) rTMS1: -8.4 rTMS2: -13.5 Sham1: -5.7 Sham2: -13.9 P = 0.14 | HAM-D_24_ Response, n (%) rTMS1: 4 (22.2%) rTMS2: 5 (31.3%) Sham1: 2 (28.6%) Sham2: 4 (57.1%) P = NR Remission: NR

HAM-D_17_ = 17-item Hamilton Depression Scale; HAM-D_21_ = 21-item Hamilton Depression Scale; Hz = hertz; LOCF = last observation carried forward; MADRS = Montgomery-Åsberg Depression Rating Scale; n = number; NR = not reported; P = p-value; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation; txt = treatment

One fair-quality trial compared 1 week of low-frequency rTMS (a group of 36, consisting of 18 who received low-frequency rTMS and 18 who received high-frequency rTMS) with 1 week of sham rTMS stimulation (involving a subgroup of 15 patients from the above group of 36 who received control treatment 8 weeks after having received rTMS).79 Patients entered treatment severely depressed (mean HAM-D_21_ severity 23.19 in rTMS group, 24.53 in sham group). No difference in decrease in HAM-D_21_ item severity was identified (-5.69 in active group, -3.40 in control group, P = not reported).

One good-quality trial compared three groups: one with high-frequency rTMS (n = 20 patients), one with low-frequency rTMS (n = 20 patients), and one with sham stimulation (n = 20 patients) following 2 weeks of treatment.80 The three groups had MADRS scores averaging between 35 and 38, consistent with severe depression. Both the high-frequency and low-frequency groups had 5 percent bipolar patients, and the control group had 20 percent. An ITT analysis favored the two rTMS groups. Both the high-frequency (-5.25) and low-frequency (-5.5) groups had greater decrease in MADRS severity than the sham group (-0.35, P < 0.005 for each comparison with control). Using a definition of response as > 20 percent improvement in MADRS score, the two active groups tended to have greater rates of response (40% and 35%, respectively) compared to the sham stimulation group (10%) (P = 0.07 for both comparisons). Using the more standard definition of response as a 50 percent decrease, only one patient (in the low frequency group) responded by study end.

Another good-quality, 6-week study compared high-frequency rTMS plus low-frequency rTMS (n = 25 patients) to sham rTMS stimulation (n = 25 patients).18 Failure was not required in the current episode. The number of treatments depended on the presence of at least partial response. Patients entering the rTMS were severely depressed (mean HAM-D_17_ of 22.5), while the control group was only moderately depressed (mean HAM-D_17_ of 19.8). Sixteen percent of each group had bipolar disorder. rTMS patients had better outcomes than patients receiving sham stimulation on each response measure. Compared to control, rTMS patients had a greater improvement in HAM-D scores (-10.2 vs. -1.1, P < 0.001), greater response rate (52% vs. 8%, P = 0.001), and a greater remission rate (40% vs. 0%, P = 0.001).

A 2-week study compared three groups: those receiving high-frequency rTMS (20 hertz [Hz]) (n = 11 patients), those receiving “lower” high-frequency rTMS (5 Hz) (n = 11 patients), and those receiving sham rTMS treatment (n = 10 patients).81 Patients entering the study were severely depressed (mean HAM-D_21_ severity for 20 Hz group 23.2, 5 Hz group 26.5, and sham group 22.7) The 20 Hz high-frequency group had 10 percent bipolar patients, and the other two group each had 20 percent with a bipolar depression. A treatment completer analysis showed that patients in the active groups had a greater decrease in HAM-D_21_ severity (-13.4 and -14.2, respectively) than the control group (-3.7, P < 0.01 for each comparison). Similarly, response favored the two rTMS groups (60% for each vs. 10% for the sham stimulations comparison, P = 0.01 for both). Finally, both rTMS treatments had greater remission rates (50%) than the sham control group, which had no remitters (P = not reported).

A fifth augmentation study compared high-frequency rTMS to the left dorsolateral prefrontal cortex (n = 18) and high-frequency rTMS to the right dorsolateral prefrontal cortex (n = 16), with sham rTMS treatments to the same locations (left n = 7, right n = 7).82 Unlike other studies comparing rTMS and sham stimulation, in this study all patients also received a social support intervention. At baseline, patients were severely depressed (HAM-D_24_ mean [SD] high rTMS 28.2 [6.0], high right rTMS 27.2 [4.8], sham left 27.7 [3.5], sham right 27.3 [2.7]), and only two patients in the high right rTMS group had bipolar disease (high right rTMS 12.5%, all other groups 0%). Patients in all groups had a decrease in depressive severity (HAM-D_24_ mean high rTMS -8.4, high right rTMS -13.5, sham left -5.7, sham right -13.9, P = NR), but patients in the active rTMS groups were not more likely to respond to treatment compared to those in the sham group (high rTMS 22.2%, high right rTMS 31.3%, sham left 28.6%, sham right 57.1%, P = 0.14). It is possible that the inclusion of a social support intervention may have muffled the effects of rTMS in this study.

##### Meta-Analytic Synthesis of Tier 1 MDD/Bipolar mix Outcomes

We were able to quantitatively synthesize outcomes from four of the five studies within an MDD/bipolar mix Tier 1 population.18,79-82 The fifth study, an outlier, was excluded from the analysis.82 Though the rTMS intervention in this study used similar stimulation parameters to others in this category, an extensive supportive social intervention distinguished it from the other trials. This additional co-intervention may have diminished the comparative efficacy of rTMS and sham stimulation. Based on these concerns and the heterogeneity introduced when this study was included, we excluded this study from the meta-analyses.

For changes in depressive severity involving the three studies using HAM-D as an outcome, patients receiving rTMS on average had approximately a 7-point greater decrease relative to sham control (-7.25, 95% CI, -10.87 to -3.64). Because sample sizes were small and responses to placebo varied in the small control groups, the heterogeneity was high (I^2^ = 90%) and our estimates are uncertain with respect to the magnitude of changes on the HAM-D. Given this uncertainty, we are not including the forest plot.

The pooled relative risk (HAM-D or MADRS) indicated that patients receiving rTMS were more than five times as likely to have a treatment response as those receiving sham treatment (5.38, 95% CI, 1.88-15.46) (Figure 8), which translates to an NNT of 3 (95% CI, 1-14).

Figure 8 Relative risk meta-analysis of response rates comparing rTMS versus sham: Tier 1, MDD/≤ 20 percent bipolar disorder

Figure 8 shows the study statistics and forest plots for the random effects meta-analysis of the relative risk for response in rTMS compared to sham in a Tier 1 MDD & Bipolar mix population. Fitzgerald et al., 2006 reports a relative risk for response of 6.50 (95%CI, 1.63 to 25.88). Fitzgerald et al., 2003 reports a relative risk for response of 1.50 (95%CI, 0.06 to 35.19). Su et al., 2006 reports a relative risk for response of 6.00 (95%CI, .89 to 40.41). Overall, the meta-analysis showed a relative risk for response of 5.38 (95%CI 1.88 to 15.46, I2 = 0%).

We were unable to quantitatively synthesize remission rates because only two studies in this population reported this outcome; both studies indicated greater absolute remission rates for rTMS compared with sham.18,81

##### Tier 1 MDD and MDD/Bipolar Combined

Meta-analyses combining TRD studies (Tier 1) from both MDD and MDD/bipolar mix populations continued to support the benefit of rTMS over sham control. The mean difference in HAM-D depressive severity was -5.74 (95% CI, -7.79 to -3.68) (Figure 9). The pooled relative risk indicated that patients receiving rTMS were more than three times as likely to respond as those receiving placebo (pooled relative risk 3.34, 95% CI, 1.92 to 5.82) (Figure 10), which translates into a NNT of 5 (95% CI, 3-10). Remission rates also favored rTMS. The pooled relative risk for remission was 6.12 (95% CI, 1.89 to 19.80), which translates to a NNT of 4 (95% CI, 2-20) (Figure 11).

Figure 9 Mean difference meta-analysis of changes in depressive severity comparing rTMS versus sham: Tier 1

Figure 9 shows the study statistics and forest plots for the random effects meta-analysis of the mean difference between rTMS and sham groups for decreases in depressive severity (on the HAM-D) in Tier1 MDD and MDD/Bipolar mix populations. For rTMS versus sham groups in an MDD/Bipolar mixed population, Bocchio-Ciavetti et al., 2008, reports a difference in means equal to -2.30 (95%CI, -5.70 to 1.10). Garcia-Toro et al., 2001 reports a difference in means equal to -5.30 (95%CI, -8.30 to -2.30). Fitzgerald, et al., 2006 reports a difference in means equal to -11.30 (95%CI, -14.67 to -7.93). Su et al., 2006 reports a difference in means equal to -8.40 (95%CI, -13.16 to -3.64). Overall, the meta-analysis showed a difference in means between rTMS and sham groups in an MDD/Bipolar mix population equal to -7.25 (95%CI -10.87 to -3.64, I2 = 0%). For rTMS versus sham groups in the MDD only population, Avery et al., 2006 reports a difference in means equal to -4.10 (95%CI, -7.48 to -0.72). Boutros et al., 2002 reports a difference in means equal to -5.60 (95%CI, -11.00 to -0.20). Garcia-Toro et al.,2006 reports a difference in means equal to -5.60 (95%CI, -10.52 to -0.68). Holtzheimer et al., 2004 reports a difference in means equal to -2.60 (95%CI, -8.98 to 3.78). Kauffmann et al., 2004 reports a difference in means equal to -4.30 (95%CI, -11.77 to 3.17). Padberg et al., 1999 reports a difference in means equal to -0.40 (95%CI, -7.59 to 6.79). Zheng et al., 2010 reports a difference in means equal to -9.40 (95%CI, -13.77 to -5.03). The meta-analysis showed a difference in means between rTMS and sham groups in an MDD only population equal to -5.01 (95%CI -7.51 to -2.52., I2 = 0%). Finally, the meta-analysis showed a difference in means between rTMS and sham groups in both MDD only and MDD/Bipolar mix populations equal to -5.74 (95%CI -7.79 to -3.68., I2 = 55%).

Figure 10 Relative risk meta-analysis of response rates comparing rTMS versus sham: Tier 1

Figure 10 shows the study statistics and forest plots for the random effects meta-analysis of the relative risk for response in rTMS compared to sham groups in both Tier1 MDD and MDD/Bipolar mix populations. For rTMS versus sham groups in an MDD/Bipolar mixed population, Fitzgerald et al., 2006 reports a relative risk for response of 6.50 (95%CI, 1.63 to 25.88). Fitzgerald et al., 2003 reports a relative risk for response of 1.50 (95%CI, 0.06 to 35.19). Su et al., 2006 reports a relative risk for response of 6.00 (95%CI, .89 to 40.41). The meta-analysis for rTMS compared to sham groups in an mixed MDD/Bipolar population showed a pooled relative risk for response of 5.38 (95%CI 1.88 to 15.46, I2 = 0%). For rTMS versus sham groups in an MDD only population, Avery et al., 2006 reports a relative risk for response of 5.19 (95%CI, 1.24 to 21.66). Boutros et al., 2002 reports a relative risk for response of 1.25 (95%CI, 0.26 to 6.07). Garcia-Toro et al., 2001 reports a relative risk for response of 5.00 (95%CI, 0.64 to 39.06). Garcia-Toro et al., 2006 reports a relative risk for response of 4.61 (95%CI, 0.27 to 77.76). Holtzheimer et al., 2004 reports a relative risk for response of 2.29 (95%CI, 0.26 to 20.13). Kauffmann et al., 2004 reports a relative risk for response of 1.43 (95%CI, 0.41 to 4.99). Pallanti et al., 2010 reports a relative risk for response of 2.75 (95%CI, 0.67 to 11.24). Zheng et al., 2010 reports a relative risk for response of 9.47 (95%CI, 1.38 to 64.90). The meta-analysis for rTMS and sham groups in an MDD only population showed a pooled relative risk for response of 2.82 (95%CI 1.57 to 5.09, I2 = 0%). Overall, the meta-analysis of rTMS versus sham groups in both MDD only and MDD/Bipolar mix populations showed a pooled relative risk for response of -3.34 (95%CI 1.92 to 5.82., I2 = 0%).

Figure 11 Relative risk meta-analysis of remission rates comparing rTMS versus sham: Tier 1

Figure 11 shows the study statistics and forest plots for the random effects meta-analysis of the relative risk for remission in rTMS compared to sham from both Tier1 MDD and MDD/Bipolar mix populations. For rTMS versus sham groups in an MDD/Bipolar mixed population, Fitzgerald et al., 2006 reports a relative risk for remission of 21.00 (95%CI, 1.30 to 339.66). Su et al., 2006 reports a relative risk for remission of 11.00 (95%CI, .68 to 176.83).The meta-analysis for rTMS compared to sham groups in mixed MDD/Bipolar populations showed a pooled relative risk for remission of 15.19 (95%CI 2.13 to 108.47, I2 = 0%). For rTMS versus sham groups in an MDD only population, Avery et al., 2006 reports a relative risk for remission of 6.60 (95%CI, .86 to 50.79). Kauffmann et al., 2004 reports a relative risk for remission of 2.86 (95%CI, 0.44 to 18.48). Pallanti et al., 2010 reports a relative risk for response of 4.00 (95%CI, 0.54 to 29.80). The meta-analysis for rTMS and sham groups in an MDD only population showed a pooled relative risk for remission of 4.12 (95%CI 1.32 to 12.84, I2 = 0%). Overall, the meta-analysis of rTMS versus sham groups in both MDD only and MDD/Bipolar mix populations showed a pooled relative risk for remission of 6.12 (95%CI 1.89 to 19.80., I2 = 0%).

MDD/bipolar mix point estimates tended to be slightly higher than those for MDD-only, but confidence intervals overlapped, suggesting no clear difference. Indeed, combining the two populations did not affect the direction nor did it substantially impact the magnitude of the results, and the combined results were consistent with what was reported for the Tier 1 syntheses separately.

#### Tier 2: Patients With one or More Treatment Failures

Consideration of Tier 2 provided six additional studies: four MDD-only studies (reported in six articles)83-87 and two additional MDD/bipolar mix studies.88,89

##### MDD-Only

Consideration of Tier 2 study populations added four additional studies reported in five articles.83-87 Two trials were rated good quality, while two were rated fair quality. All employed switch strategies, and evaluated rTMS versus sham stimulation in patients with one or more treatment failures (Table 20).

Table 20 Efficacy of rTMS versus sham: Tier 2, MDD

Author, Year Endpoint Current Episode Failure Requirement Quality | Intervention and Sample Size Study Details | Population characteristics | Change in depressive symptoms | Response Remission
George et al., 2010^83^ Up to 6 weeks, mITT Did not require failure in the current episode Good | rTMS (n = 92*) High frequency, 15 sessions Sham (n = 98*) *mITT (N randomized = 199) Treatment strategy Switch Definitions Remission definition HAM-D_24_ < 10 at two consecutive visits | Mean failed antidepressant trials: Current/lifetime rTMS: 1.62/3.34 Sham: 1.41/3.28 Baseline Depression HAM-D_24_, mean (SD) rTMS: 26.3 (5.0) Sham: 26.5 (4.8) | HAM-D_24_ At 3 weeks Change**, mean (SD) rTMS: -4.7 Sham: -3.1 **observed rTMS n = 83 Sham n = 91 95% CI effect estimate (adjusted) -4.23 to 0.10, P = 0.06 | HAM-D_24_ Response*, n (%) rTMS: 14 (15.2) Sham: 5 (5.1) OR, 4.6 (95% CI, 1.47-14.42) Remission*, n (%) rTMS: 13 (14.1) Sham: 5 (5.1) OR, 4.18 (95% CI, 1.32-13.24)
Manes et al., 2001^84^ and Moser et al., 2002^85^ 1 week, all reported patients included in analysis Did not require failure in the current episode Fair | rTMS (n = 10) High frequency, 5 sessions Sham (n = 10) Treatment strategy Switch Definitions Response definition: 50% reduction in HAM-D and no longer met DSM criteria for major or minor depression Remission definition: HAM-D < 8 | Diagnosis Major Depression,% rTMS: 80 Sham: 100 Dysthymia,% rTMS: 20 Sham: 0 Mean number of failed antidepressant trials: rTMS: 4 (2.3) Sham: 4 (1.2) Baseline Depression HAM-D NR, mean (SD) rTMS: 22.7 (5.2) Sham: 22.7 (7.1) | HAM-D NR Change, mean (SD) rTMS: -9 Sham: -6.5 P >0.66 | HAM-D NR Response, n (%) rTMS: 3 (30) Sham: 3 (30) P = NS Remission, n (%) rTMS: 2 (20) Sham: 2 (20) P = NR
Stern et al., 2007^86^ 2 weeks, all reported patients included in analysis Required failure in the current episode Fair | rTMS -1(n = 10) High frequency,10 sessions rTMS -2(n = 10) Low frequency (1 Hz), Left-DLPFC, 10 sessions rTMS-3 (n = 10) Low frequency, 10 sessions Sham (n = 15) Treatment strategy Switch Definitions Remission definition HAM-D_21_ ≤ 10 | Mean number of failed antidepressant trials: rTMS-1: NR rTMS-2: NR rTMS-3: NR Baseline Depression HAM-D_21_, mean (SD) rTMS-1: 27.8 (3.2) rTMS-2: 27.6 (3.9) rTMS-3: 27.9 (3.8) Sham: 27.4 (2.9) | HAM-D_21_ Change, mean (SD) rTMS-1: -12.7 rTMS-2: 0.0 rTMS-3: -12.1 Sham: -0.7 rTMS-1 > rTMS-2 + sham and rTMS > rTMS-2 + sham, P < 0.0005 | HAM-D_21_ Response, n (%) rTMS-1: 5 (50) rTMS-2: 0 (0) rTMS-3: 5 (50) Sham: 0 (0) P = NR Remission, n (%) rTMS-1: 3 (30) rTMS -2: 0 (0) rTMS -3: 1 (10) Sham: 0 (0) P = NR
O'Reardon, 2007^87^ 6 weeks; at week 4, patients not responding left study with LOCF, mITT Did not require failure in the current episode Good | rTMS (n = 165) High frequency, up to 30 sessions Sham (n = 160) Treatment strategy Switch Definitions Remission definition: HAM-D_17_ ≤ 7 | Mean number of failed antidepressant trials: rTMS: 1.6 Sham: 1.6 Baseline Depression HAM-D_17_, mean (SD) rTMS: 22.6 (3.3) Sham: 22.9 (3.5) | HAM-D_17_* Change, mean (SD) rTMS:-5.5 Sham:-3.3 P = 0.005 *Results based on rTMS: n = 155 Sham: n = 146 | HAM-D_17_* Response, n (%) rTMS: 38 (24.5) Sham: 20 (13.7) P < 0.05 Remission, n (%) rTMS: 24 (15.5) Sham: 13 (8.9) P = 0.065

DLPFC = dorsolateral prefrontal cortex; DSM = Diagnostic and Statistical Manual; HAM-D = Hamilton Depression Scale; HAM-D_21_ = 21-item Hamilton Depression Scale; Hz = hertz; LOCF = last observation carried forward; mITT = modified intention to treat; n = number; NR = not reported; P = p-value; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation

A large study, rated to be of good quality, compared up to 6 weeks of high frequency (n = 93) with sham rTMS stimulation (n = 98).83 On average, patients in the trial had moderate to severe depression (mean HAM-D_24_ rTMS 26.3 sham 26.5) and had three antidepressant failures in their lifetime (rTMS 3.34 sham 3.28). Using a modified ITT analysis, patients in the rTMS group had a greater decrease in depressive severity (at week 3, rTMS -4.7 sham -3.3, P = 0.06) and higher rates of response (OR, 4.6 [95% CI, 1.47-14.42]) and remission (OR, 4.18 [95% CI, 1.32-13.24].

A brief 1-week trial compared high-frequency rTMS (n = 10 patients) to sham stimulation (n = 10 patients).84,85 Enrolled patients had moderate to severe depression (mean HAM-D severity approximately 23 in each group). Whether the analysis conducted was ITT or treatment completer was not clear. Results demonstrated no difference between the rTMS and sham groups in the decrease of depressive severity (-9 vs. -6.5, P > 0.66), the rate of response (30% in each), or the rate of remission (20% in each).

The largest trial the second good-was a 4-week study comparing high-frequency rTMS (n = 165 patients) to sham stimulation (n = 160 patients).87 Patients were required to have at least one but not more than four failed adequate antidepressant treatments in this or the most recent episode or to have failed to tolerate four adequate lifetime medication trials. The groups participating were severely depressed (mean HAM-D_17_ approximately 23). A modified ITT analysis involving 301 patients at 6 weeks favored rTMS, which showed a greater decrease in depressive severity (mean HAM-D_17_ decrease of 5.5 versus 3.3, P = 0.005) and a greater response rate (24.5% vs. 13.7%, P < 0.05), while there was a trend toward greater remission rates with rTMS (15.5% vs. 8.9%, P = 0.065).

The fifth trial compared 2 weeks of rTMS stimulation among four groups: high-frequency rTMS (n = 10 patients), low frequency left-sided rTMS (n = 10 patients), low frequency right-sided rTMS (n = 10 patients), and sham control (n = 15 patients).86 All patients had been referred for ECT following treatment failure of an adequate course of an antidepressant medication. The groups involved were severely depressed (mean HAM-D_21_ item ranged between 27 and 28 for each group). It was unclear whether the analysis conducted was ITT or treatment completers. For each outcome, the high-frequency rTMS and the low-frequency rTMS groups appeared to produce better outcomes than the low frequency left-sided rTMS and sham groups. The high left-sided rTMS and low right-sided rTMS groups produced a greater decrease in depressive severity than the low left rTMS or sham group (mean change in HAM-D_21_ high rTMS > low left rTMS + sham and low right rTMS > low left rTMS + sham, P < 0.0005). Response rates (50% and 50% vs. 0% and 0%, P = not reported) and remission rates (30% and 10% vs. 0% and 0%; P = not reported) also appeared higher in the same two groups.

##### MDD/Bipolar

Consideration of Tier 2 added two MDD/bipolar mix studies. The first was a 2-week switch study comparing high-frequency rTMS (n = 10 patients) to sham rTMS treatment (n = 10 patients).88 This study is summarized in Table 21, with a detailed description provided in the evidence tables (Appendix E). All patients had at least one treatment failure following an adequate antidepressant trial during the current episode except one, who had previously received ECT and had proven treatment resistant to antidepressants in the past). Patients entered into the study with a severe degree of depression (approximately 37 on the HAM-D_25_ item scale in each group). As with the Tier 1 group, the rTMS group had a mean HAM-D_25_ decrease of 14 compared to a decrease of 0.2 in the control group (P < 0.01). Response rates also favored rTMS (10% vs. 0%, P = 0.09).

Table 21 Efficacy of rTMS versus sham: Tier 2 MDD and ≤ 20 percent bipolar disorder

Author, Year Endpoint Current Episode Failure Requirement Quality | Intervention and Sample Size Study Details | Population characteristics | Change in depressive symptoms | Response Remission
Berman et al., 2000^88^ 2 weeks Did not require failure in the current episode Fair | rTMS (n = 10) High frequency, 10 sessions Sham (n = 10) Treatment strategy Switch | Diagnosis Bipolar (%) rTMS: 0 Sham: 10 Mean number of failed antidepressant trials: rTMS: 5 Sham: 3.5 (plus 1 failed augmentation medication each) Baseline Depression HAM-D_25_, mean rTMS: 37.1 Sham: 37.3 | HAM-D_25_ Change, mean* (SEM) rTMS: -14.0 (3.7) Sham: -0.2 (4.1) P < 0.01 *adjusted mean decreases based on best fit slopes | HAM-D_25_ Response, n (%) rTMS: 1 (10) Sham: 0 (0) P = 0.09
Bretlau et al., 2008^89^ 3 weeks, mITT Required failure in the current episode. Fair | rTMS (n = 25) High frequency, 15 sessions over 3 weeks Sham (n = 24) 20 mg escitalopram Treatment Strategy Combination all patients received 20 mg escitalopram | Previous manic episodes: rTMS: 4.5% Sham: 13.0% Mean number of failed antidepressant trials (current episode): rTMS: 2.8 (0.9) Sham: 2.5 (0.9) Baseline Depression: HAM-D_17_, mean* (SD) rTMS: 25.3 (3.0) Sham: 24.7 (3.2) *based on rTMS: n = 22 Sham: n = 23 | HAM-D_17_ Change, mean* (SD) rTMS: -8.9 Sham: -5.6 Effect size: 0.78 (0.18-1.39)* | HAM-D_17_ Response, n (%) NR Remission, n (%) NR

HAM-D_17_ = 17-item Hamilton Depression Scale; HAM-D_25_ = 25-item Hamilton Depression Scale; mITT = modified intention to treat; n = number; rTMS = repetitive transcranial magnetic stimulation; SEM = standard error of measurements

Over a duration of 3 weeks, the second study compared the combination of high-frequency rTMS plus escitalopram (n = 25 patients) with sham rTMS plus escitalopram (n = 24 patients) in patients who had discontinued their previous antidepressant pharmacotherapy (failed within the current episode).89 Those participating were moderately to severely depressed (mean HAM-D_17_ was 25.3 [SD 3.0] in rTMS group and 24.7 [SD 3.2] in the sham control). Authors conducted a modified ITT analysis. Mean depressive severity change was -8.9 in the rTMS escitalopram group and -5.6 in the sham alone group. This comparison favored rTMS plus pharmacotherapy over pharmacotherapy alone with the authors reporting an effect size of 0.78 (95% CI, 0.18 to 1.39).

#### Tier 3: Patients With Probable TRD

Three trials comparing rTMS with sham stimulation were identified in Tier 3 (Table 22).

Table 22 Efficacy of rTMS versus sham: Tier 3 MDD and ≤ 20 percent bipolar disorder

Author, year Study Design Primary endpoint(s) Quality Tier | Intervention and Sample Size Study Details | Population Characteristics | Change in Depressive Symptoms | Response Remission
Bortolomasi et al., 2006^90^ 1 week, all reported patients included in analysis Did not require failure in the current episode Tier 3—“drug resistance” not defined Fair | rTMS (n = 12) High frequency, 5 sessions Sham (n = 7) Treatment strategy Augmentation | Diagnosis Bipolar (%) rTMS: 16.7 Sham: 14.3 Mean number of failed antidepressant trials: rTMS: NR Sham: NR Baseline Depression: HAM-D_24_ rTMS: 25.17 Sham: NR | HAM-D_24_ Change, mean (SD) rTMS: -13.84 Sham: NR P = data NR but text states not significant | HAM-D_24_ Response, n (%) NR Remission, n (%) NR
George et al., 1997^91^ Crossover, 2 weeks Tier 3—all patients had 1+ implied current episode failures Fair | rTMS (n = 12) High frequency, 10 sessions Sham (n = 12) Treatment strategy Mixed-within group difference Patients discontinued their (failed) ADs with the exception of 3 patients who were partial responders | Diagnosis Bipolar (%) Overall: 8.3 Mean number of failed antidepressant trials: Overall: 13.4 Baseline Depression: HAM-D_21_ Overall: 28.5 (4.2) | HAM-D_21_ Change, mean (SD) rTMS: -5.25 Sham: +3.33 P < 0.03 | HAM-D_21_ Response, n (%) NR Remission, n (%) NR
Moller, 2006^92^ Crossover, within 1 week of completing 1 week of txt Did not require failure in the current episode. Tier 3—TRD not defined Fair | rTMS (n = 10) High frequency, 5 sessions Sham (n = 10) Treatment strategy Augmentation | Diagnosis Bipolar (%) Overall: 20 Mean number of failed antidepressant trials: rTMS: NR Sham: NR Baseline Depression: HAM-D_17_ Median (range) rTMS: 20 (13-37) Sham: 16 (7-31) | HAM-D_17_ Change (median) rTMS: -7 Sham: -1 P = 0.075 | HAM-D_17_ Response, n (%) NR Remission, n (%) NR

Ads = antidepressants; ; HAM-D_17_ = 17-item Hamilton Depression Scale; HAM-D_21_ = 21-item Hamilton Depression Scale; HAM-D_24_ = 24-item Hamilton Depression Scale; n = number; NR = not reported; P = p-value; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation; TRD = treatment-resistant depression; txt = treatment

##### MDD-Only

There were no eligible studies.

##### MDD/Bipolar

Three small studies compared rTMS versus a sham control; these studies are summarized in Table 22 and described in detail in the evidence tables (Appendix E). Two studies reported significantly better outcomes for rTMS and the third identified a trend in this direction. Results did not vary by strategy. Study duration did not appear to affect outcomes.

With the exception of a control arm in one study, all groups were severely depressed. All studies used high-frequency rTMS and none required treatment failure in the current episode.

One study compared 5 sessions per week of high-frequency rTMS (n = 12 patients) to sham stimulation (n = 7 patients).90 The authors indicated that patients needed to meet criteria for “drug resistance,” but this definition was not provided. Patients enrolled were depressed (mean HAM-D_24_ for rTMS group = 25.17). Those receiving rTMS had a greater decrease in mean HAM-D_24_ severity than those in the control group (the text states that the difference is statistically significant, but it does not report the test).

The other augmentation trial was a small randomized crossover study that compared patients (n = 10) receiving 1 week of high-frequency versus sham stimulation.100 Patients were referred to the study because their depression was “drug resistant,” and the authors note that “various antidepressants had previously been tried without adequate success.” On average, patients entering the study were moderately to severely depressed (median HAM-D_17_ for sham = 16 [moderate] and for rTMS = 20 [severe]). Outcomes suggested benefit for rTMS as measured by mean change in depressive severity (-7 vs. -1), but in this small sample this difference was insignificant (P = 0.075).

A third trial tested a mixed strategy that also used a crossover design. The study (n = 12 patients) compared 2-week outcomes for patients who received, in randomized order, 2 weeks of high-frequency rTMS and 2 weeks of sham rTMS stimulation.91 All patients still met criteria for a major depressive episode despite treatment with an antidepressant, suggesting failure in the current episode. Patients entering the trial were severely depressed (mean HAM-D_21_ score = 28.5). Results from an ITT analysis favored active treatment; the rTMS group had a greater mean change in depressive severity (-5.25 vs. + 3.33, P < 0.03).

#### Tiers 1-3 Combined

Twenty-four studies comparing rTMS with sham rTMS stimulation were identified.18,69-82,84-88,90,91 The majority of studies for this comparison found that rTMS resulted in significantly greater efficacy as measured by change in depressive severity, response, and remission. Other studies did not report tests of statistical significance or were underpowered to detect differences between groups. Differences in efficacy by tier and inclusion of patients with bipolar disorder were assessed via stratified meta-analyses.

##### Meta-Analytic Synthesis of Outcome in an MDD-Only Population (Tiers 1, 2, and 3 Combined)

Meta-analyses combining studies from only Tier 1 and Tier 2 studies (as there were no Tier 3 studies identified) supported the benefit of rTMS over sham control and were consistent with Tier 1 analyses. The weighted mean difference in HAM-D depressive severity was -4.40 (95% CI, -6.04 to -2.76) (Figure 12). The pooled relative risk indicated that patients receiving rTMS were approximately twice as likely to respond as those receiving placebo (pooled relative risk 2.18, 95% CI, 1.47 to 3.22) (Figure 13), which translates into a NNT of 6 (95% CI, 4—10). Pooled relative risk for remission rates only slightly favored rTMS at 2.37 (95% CI, 1.20 to 4.69) (Figure 14).

Figure 12 Mean difference meta-analysis of changes in depressive severity comparing rTMS with sham: Tiers 1 & 2, MDD

Figure 12 shows the study statistics and forest plots for the random effects meta-analysis of the mean difference between rTMS and sham groups for decreases in depressive severity (on the HAM-D) in Tier 1 & Tier 2 MDD only population. For the comparing rTMS with sham in MDD only, Tier 1 studies, Avery et al., 2006 reports a difference in means equal to -4.10 (95%CI, -7.48 to -0.72). Boutros et al., 2002 reports a difference in means equal to -5.60 (95%CI, -11.00 to -0.20). Garcia-Toro et al., 2001 reports a difference in means equal to -5.30 (95%CI, -8.30 to -2.30). Garcia-Toro et al.,2006 reports a difference in means equal to -5.60 (95%CI, -10.52 to -0.68). Holtzheimer et al., 2004 reports a difference in means equal to -2.60 (95%CI, -8.98 to 3.78). Kauffmann et al., 2004 reports a difference in means equal to -4.30 (95%CI, -11.77 to 3.17). Padberg et al., 1999 reports a difference in means equal to -0.40 (95%CI, -7.59 to 6.79). Zheng et al., 2010 reports a difference in means equal to -9.40 (95%CI, -13.77 to -5.03). The meta-analysis for rTMS and sham groups Tier 1 studies in MDD only populations showed a difference in means equal to -5.18 (95%CI -6.79 to -3.58, I2 = 0%). For the comparing rTMS with sham in MDD only, Tier 2 studies, George et al., 2006 reports a difference in means equal to -1.57(95%CI, -3.37 to .23). Manes, et al., 2001 reports a difference in means equal to -2.50(95%CI, -8.07 to 3.07). O'Reardon, et al.,2007 reports a difference in means equal to -2.20(95%CI, -3.58 to -0.82). Stern, et al., 2007 reports a difference in means equal to -12.00(95%CI, -16.94 to -7.06). The meta-analysis for rTMS and sham groups Tier 2 studies in MDD only populations showed a difference in means equal to -3.55 (95%CI -6.02 to -1.09, I2 = 0%). Overall, the meta-analysis of rTMS versus sham groups, Tiers 1 and 2 in MDD only populations showed a difference in means equal to -4.40 (95%CI -6.04 to 2.76., I2 = 63%).

Figure 13 Relative risk meta-analysis of response rates comparing rTMS with sham: Tiers 1 & 2, MDD

Figure 13 shows the study statistics and forest plots for the random effects meta-analysis of the relative risk for response in rTMS compared to sham groups in both Tier1 and Tier 2 MDD only populations. For rTMS versus sham groups in the Tier one MDD only population studies, Avery et al., 2006 reports a relative risk for response of 5.19 (95%CI, 1.24 to 21.66). Boutros et al., 2002 reports a relative risk for response of 1.25 (95%CI, 0.26 to 6.07). Garcia-Toro et al., 2001 reports a relative risk for response of 5.00 (95%CI, 0.64 to 39.06). Garcia-Toro et al., 2006 reports a relative risk for response of 4.61 (95%CI, 0.27 to 77.76). Holtzheimer et al., 2004 reports a relative risk for response of 2.29 (95%CI, 0.26 to 20.13). Kauffmann et al., 2004 reports a relative risk for response of 1.43 (95%CI, 0.41 to 4.99). Pallanti et al., 2010 reports a relative risk for response of 2.75 (95%CI, 0.67 to 11.24). Zheng et al., 2010 reports a relative risk for response of 9.47 (95%CI, 1.38 to 64.90). The meta-analysis for rTMS and sham, groups in Tier 1 MDD only population showed a pooled relative risk for response of 2.82 (95%CI 1.57 to 5.09, I2 = 0%). %). For the comparing rTMS with sham in MDD only, Tier 2 studies, George et al., 2006 reports a relative risk for response of 2.13 (95%CI, .76 to 6.00). Manes, et al., 2001 reports a relative risk for response of 1.00 (95%CI, .26 to 3.81). O'Reardon, et al.,2007 reports a relative risk for response of 1.84 (95%CI, 1.12 to 3.03). Stern, et al.,2007 reports a relative risk for response of 15.88 (95%CI, 1.01 to 250.69). The meta-analysis for rTMS and sham groups Tier 2 studies in MDD only population showed a pooled relative risk for response of 1.87 (95%CI 1.23 to 2.84, I2 = 0%). Overall, the meta-analysis of rTMS versus sham groups, Tiers 1 and 2 in MDD only population showed a pooled relative risk for response of 2.18 (95%CI 1.47 to 3.22, I2 = 0%).

Figure 14 Relative risk meta-analysis of remission rates comparing rTMS with sham: Tiers 1 & 2, MDD

Figure 14 shows the study statistics and forest plots for the random effects meta-analysis of the relative risk for remission in rTMS compared to sham in a Tier 1 and Tier 2 MDD only population. Avery et al., 2006 reports a relative risk for remission of 6.60 (95%CI, .86 to 50.79). Kauffmann et al., 2004 reports a relative risk for remission of 2.86 (95%CI, 0.44 to 18.48). Pallanti et al., 2010 reports a relative risk for remission of 4.00 (95%CI, 0.54 to 29.80). The meta-analysis for rTMS and sham groups in Tier 1 studies in an MDD only population showed a pooled relative risk for remission of 4.12 (95%CI 1.32 to 12.84, I2 = 0%). For comparing rTMS with sham in MDD only Tier 2 studies, George et al., 2006 reports a relative risk for remission of 3.20 (95%CI, .66 to 15.43). Manes, et al., 2001 reports a relative risk for remission of 1.00 (95%CI, .17 to 5.77). O'Reardon, et al., 2007 reports a relative risk for remission of 1.79 (95%CI, 0.94 to 3.39). Stern, et al.,2007 reports a relative risk for response of 6.91 (95%CI, .40 to 119.46). The meta-analysis for rTMS and sham groups Tier 2 studies in MDD only populations showed a pooled relative risk for remission of 1.91 (95%CI 1.10 to 3.31 , I2 = 0%). Overall, the meta-analysis of rTMS versus sham groups, Tiers 1 and 2 in MDD only populations showed a pooled relative risk for remission of 2.37 (95%CI 1.20 to 4.69, I2 = 0%).

Combining these three tiers for MDD-only populations provided a more conservative point estimate and a narrower confidence interval for each of the three outcomes than the quantitative syntheses for Tier 1 MDD-only.

##### Meta-Analytic Synthesis of MDD/Bipolar mix Outcomes (Tiers 1, 2, and 3 Combined)

Meta-analyses combining studies from all tiers in this population allowed for comparisons of response and remission in Tier 1 and Tier 2 studies and for change in depressive severity within all three tiers. Combining this data with Tier 1 results continued to support benefit for rTMS. For changes in depressive severity as measured by the mean HAM-D difference, patients receiving rTMS on average had a decrease of nearly 8 points relative to sham control (-7.73, 95% CI, - 13.31 to -2.14). Because sample sizes were small and responses to placebo varied in the small control groups, the heterogeneity was high (I^2^ = 90%) and our estimates are uncertain with respect to the magnitude of changes on the HAM-D. Given this uncertainty, we are not including the forest plot.

Response rates also favored rTMS, with rTMS groups being more than five times as likely to achieve response (random effects relative risk 5.07, 95% CI, 1.87 to 13.74) (Figure 15), leading to a NNT of 3 (95% CI, 1-14). We were unable to quantitatively synthesize remission results due to the small number of studies reporting this outcome.

Figure 15 Relative risk meta-analysis of response rates comparing rTMS with sham: Tiers 1 & 2, MDD/≤ 20 percent bipolar disorder

Figure 15 shows the study statistics and forest plots for the random effects meta-analysis of the relative risk for response in rTMS compared to sham groups in both Tier1 and Tier 2 MDD/Bipolar population. For rTMS versus sham groups in the Tier one MDD/Bipolar population studies, Fitzgerald et al., 2006 reports a relative risk for response of 6.50 (95%CI, 1.63 to 25.88). Fitzgerald et al., 2003 reports a relative risk for response of 1.50 (95%CI, 0.06 to 35.19). Su et al., 2006 reports a relative risk for response of 6.00 (95%CI, .89 to 40.41). The meta-analysis for rTMS and sham groups Tier 1 studies in an MDD/Bipolar population showed a pooled relative risk for response of 5.38 (95%CI 1.88 to 15.46, I2 = 0%). For rTMS versus sham groups in the Tier 2 MDD/Bipolar population study, Berman et al., 2000 reports a relative risk for response of 3.00 (95%CI, .14 to 65.90). The meta-analysis for rTMS and sham groups in the Tier 2 study in an MDD/Bipolar population showed a relative risk for response of 3.00 (95%CI, .14 to 65.90). Overall, the meta-analysis of rTMS versus sham groups, Tiers 1 and 2 in MDD/Bipolar population showed a pooled relative risk for response of 5.07 (95%CI 1.87 to 13.74, I2 = 0%).

Compared to the meta-analytic synthesis of Tier 1 MDD/bipolar mix studies, the combination of Tiers 1–3 produced nearly identical point estimates for change in depressive severity and response rate and narrower confidence intervals.

##### Meta-Analytic Synthesis of MDD and MDD/Bipolar mix Outcomes (Tiers 1, 2, and 3 Combined)

Meta-analyses combining studies from all tiers involved and including both MDD and MDD/bipolar mix populations continued to support the benefit of rTMS over sham control and were consistent with Tier 1 combined analyses. Most studies showed a significantly greater decrease in depressive severity in the rTMS group. The weighted mean difference in HAM-D depressive severity was -5.92 (95% CI, -8.15 to -3.70). Because sample sizes of individual studies were small and responses to placebo varied in the small control groups, the heterogeneity was high (I^2^ = 80%) and our estimates are uncertain with respect to the magnitude of changes on the HAM-D. Given this uncertainty, we are not including the forest plot.

The pooled relative risk indicated that patients receiving rTMS were more than twice as likely to respond as those receiving placebo (pooled relative risk 2.68, 95% CI, 1.52-4.70) (Figure 16), which translates into a NNT of 5 (95% CI, 4-9). Remission rates also favored rTMS. The pooled relative risk for remission was 3.73 (95% CI, 1.23-11.30), which translates to an NNT of 6 (95% CI, 3-50) (Figure 17).

Figure 16 Relative risk meta-analysis of response rates comparing rTMS with sham: Tiers 1 & 2, all populations

Figure 16 shows the study statistics and forest plots for the random effects meta-analysis of the relative risk for response in rTMS compared to sham groups in both Tier1 and Tier 2 in an MDD & MDD/Bipolar mixed populations. For rTMS versus sham groups in the Tier one MDD/Bipolar population studies, Fitzgerald et al., 2006 reports a relative risk for response of 6.50 (95%CI, 1.63 to 25.88). Fitzgerald et al., 2003 reports a relative risk for response of 1.50 (95%CI, 0.06 to 35.19). Su et al., 2006 reports a relative risk for response of 6.00 (95%CI, .89 to 40.41). The meta-analysis for rTMS and sham groups Tier 1 studies in an MDD/Bipolar population showed a pooled relative risk for response of 5.38 (95%CI 1.88 to 15.46, I2 = 0%). For rTMS versus sham groups in the Tier 2 MDD/Bipolar population study, Berman et al., 2000 reports a relative risk for response of 3.00 (95%CI, .14 to 65.90). The meta-analysis for rTMS and sham groups in the Tier 2 study in an MDD/Bipolar population showed a relative risk for response of 3.00 (95%CI, .14 to 65.90). For rTMS versus sham groups in the Tier one MDD only population studies, Avery et al., 2006 reports a relative risk for response of 5.19 (95%CI, 1.24 to 21.66). Boutros et al., 2002 reports a relative risk for response of 1.25 (95%CI, 0.26 to 6.07). Garcia-Toro et al., 2001 reports a relative risk for response of 5.00 (95%CI, 0.64 to 39.06). Garcia-Toro et al., 2006 reports a relative risk for response of 4.61 (95%CI, 0.27 to 77.76). Holtzheimer et al., 2004 reports a relative risk for response of 2.29 (95%CI, 0.26 to 20.13). Kauffmann et al., 2004 reports a relative risk for response of 1.43 (95%CI, 0.41 to 4.99). Pallanti et al., 2010 reports a relative risk for response of 2.75 (95%CI, 0.67 to 11.24). Zheng et al., 2010 reports a relative risk for response of 9.47 (95%CI, 1.38 to 64.90). The meta-analysis for rTMS and sham, groups in Tier 1 MDD only population showed a pooled relative risk for response of 2.82 (95%CI 1.57 to 5.09, I2 = 0%). For the comparing rTMS with sham in MDD only, Tier 2 studies, George et al., 2006 reports a relative risk for response of 2.13 (95%CI, .76 to 6.00). Manes, et al., 2001 reports a relative risk for response of 1.00 (95%CI, .26 to 3.81). O'Reardon, et al.,2007 reports a relative risk for response of 1.84 (95%CI, 1.12 to 3.03). Stern, et al.,2007 reports a relative risk for response of 15.88 (95%CI, 1.01 to 250.69). The meta-analysis for rTMS and sham groups Tier 2 studies in MDD only population showed a pooled relative risk for response of 1.87 (95%CI 1.23 to 2.84, I2 = 0%). Overall, the meta-analysis of rTMS versus sham groups, Tiers 1 and 2 in an MDD only and a mixed MDD/Bipolar population showed a pooled relative risk for response of 2.68 (95%CI 1.52 to 4.70, I2 = 0%).

Figure 17 Relative risk meta-analysis of remission rates comparing rTMS with sham: Tiers 1 & 2, all populations

Figure 17 shows the study statistics and forest plots for the random effects meta-analysis of the relative risk for remission in rTMS compared to sham in Tier 1 and Tier 2 MDD only & mixed MDD/Bipolar populations. For Tier 1 MDD/Bipolar studies, Fitzgerald et al., 2006 reports a relative risk for remission of 21.00 (95%CI, 1.30 to 339.66). Su et al., 2006 reports a relative risk for remission of 11.00 (95%CI, .68 to 176.83).The meta-analysis for Tier 1 rTMS versus sham groups studies in an MDD/Bipolar population showed a pooled relative risk for remission of 15.19 (95%CI 2.13 to 108.47, I2 = 0%). For Tier 1 MDD only studies, Avery et al., 2006 reports a relative risk for remission of 6.60 (95%CI, .86 to 50.79). Kauffmann et al., 2004 reports a relative risk for remission of 2.86 (95%CI, 0.44 to 18.48). Pallanti et al., 2010 reports a relative risk for remission of 4.00 (95%CI, 0.54 to 29.80). The meta-analysis for rTMS and sham groups in Tier 1 studies of an MDD only population showed a pooled relative risk for remission of 4.12 (95%CI 1.32 to 12.84, I2 = 0%). For comparing rTMS with sham in MDD only Tier 2 studies, George et al., 2006 reports a relative risk for remission of 3.20 (95%CI, .66 to 15.43). Manes, et al., 2001 reports a relative risk for remission of 1.00 (95%CI, .17 to 5.77). O'Reardon, et al., 2007 reports a relative risk for remission of 1.79 (95%CI, 0.94 to 3.39). Stern, et al., 2007 reports a relative risk for response of 6.91 (95%CI, .40 to 119.46). The meta-analysis for rTMS and sham groups Tier 2 studies in an MDD only population showed a pooled relative risk for remission of 1.91 (95%CI 1.10 to 3.31 , I2 = 0%). Overall, the meta-analysis of rTMS versus sham groups, Tiers 1 and 2 in MDD only & mixed MDD/Bipolar populations showed a pooled relative risk for remission of 3.73 (95%CI 1.23 to 11.30, I2 = 0%).

Compared to Tier 1 syntheses of MDD and MDD/bipolar populations combined, consideration of all three tiers provided more conservative point estimates and narrower confidence intervals for each outcome. Indeed, the meta-analytic results for MDD and MDD/bipolar mix for all tiers combined were most nearly identical to results for the Tier 1 MDD-only group, our main population of interest.

##### Summary of key Variables

Consideration of all tiers together for the combined MDD and MDD/bipolar mix populations provided results consistent with those from Tier 1 alone but with more conservative point estimates and narrower confidence intervals, suggesting that results from analyses of studies from all tiers reflect what can be expected in TRD (Tier 1) populations. This finding of all tier evidence reflecting what was found with Tier 1 alone held whether the population included was MDD-only or MDD/bipolar mix.

Results from Tiers 1–3 for MDD-only were in the same direction as and of similar magnitude to those for Tier 1–3 MDD/bipolar mix populations. For each outcome, point estimates for the MDD/bipolar mix group were higher with wider confidence intervals, but they were not significantly different from the MDD-only group. When these results were combined, confidence intervals were either equivalent or narrower than when the diagnostic samples were split, suggesting that combining MDD and MDD/bipolar presentations was reasonable.

Only three studies required an antidepressant failure in the current episode;73,79,86 there was no clear variation in treatment efficacy between these studies and those not requiring a current episode failure.

At baseline almost all study populations had severe depression,18,69-71,74-77,79-81,83,86-88,91 a few had moderate-to-severe depression,72,73,84,85,90,92 and in one study population, severity was not reported.78 With little variation in depression severity, we were unable to detect any differences by this variable.

In this comparison, 11 studies used an augmentation strategy,18,69-75,79-81,90,92 5 used a switch strategy,76,84-88 3 used a mixed strategy with within-group differences,77,78,91 and 1 used a combination strategy with all patients starting a new antidepressant at study entry.83 We were unable to detect clear differences by treatment characteristics (i.e., pharmacotherapy strategy, rTMS frequency, or treatment duration) through qualitative analysis due to other potentially confounding variables resulting from study design or participant characteristics.

### Vagus Nerve Stimulation Versus Sham

#### Tier 1 Patients With two or More Treatment Failures

One trial comparing VNS plus treatment as usual with treatment as usual was identified in Tier 1 (Table 23).98

Table 23 Efficacy of VNS versus sham: Tiers 1-3

Author, Year Endpoint Current Episode Failure Requirement Quality | Intervention and Sample Size Study Details | Population Characteristics | Change in Depressive Symptoms | Response Remission
Rush et al., 2005^98^ 10 weeks, mITT/per medication protocol Required failure in the current episode Good | VNS (n = 119) 10 weeks of VNS therapy with continued medications. Sham (n = 116) Treatment strategy Augmentation | Diagnosis Bipolar (%) VNS: 11.7 Sham: 9.1 Number of failed antidepressant trials (% ≥ 4): ECT: 46.5% rTMS: 40.0% Baseline Depression HAM-D_24_, mean (SD) VNS: 28.8 (5.3) Sham: 29.7 (5.2) | HAM-D_24_* % Change, mean (SD) VNS: -16.3 (28.1) Sham: -15.3 (25.5) P = 0.639 *based on VNS n = 112, sham n = 110 | HAM-D_24_* Response, n (%) VNS: 17 (15.2) Sham: 11 (10.0) P = 0.25

HAM-D_24_ = 24-item Hamilton Depression Scale; mITT = modified intention to treat; P = p-value; SD = standard deviation; VNS = vagus nerve stimulation

##### MDD-Only

There were no eligible studies.

##### MDD/Bipolar

One good 10-week study compared VNS (n = 119 patients) to a control group (n = 116 patients).98 This study is summarized in Table 23 with a detailed description provided in the evidence tables (Appendix E). The control group had the surgical procedure to implant the VNS device, but they did not have the device turned on for the sessions. Patients were required to have had an unsatisfactory response to at least two adequate trials of antidepressant medication, but not more than six failures, for the current episode. More than 40 percent of the sample had four or more prior antidepressant treatment failures, indicating a high degree of treatment resistance. The two groups entering into this study were severely depressed, with a mean HAM-D_24_ score of 28.8 in the VNS group and 29.7 in the control. In a modified ITT analysis that excluded those noncompliant with the medication protocol, the results did not demonstrate a statistically significant difference between the two groups for the primary outcome (HAM-D_24_). No differences were found in the percentage change in depressive severity (-16.3% for VNS vs. - 15.3% for control, P = 0.639) or the response rates (15.2% vs. 10.0%, P = 0.25). Of note, response rates for a secondary outcome, the 30-item Inventory for Depressive Symptomatology-self report, favored VNS (17.0% vs. 7.3%, P = 0.032).

#### Tier 2: Patients With one or More Failures

There were no eligible studies.

#### Tier 3: Patients With Probable TRD

There were no eligible studies.

#### Tiers 1-3: Combined Results

Only one study comparing VNS to sham stimulation was identified.98 This study is described in the section above.

### Psychotherapy Versus Control

#### Tier 1: Patients With two or More Treatment Failures

There were no eligible studies.

#### Tier 2: Patients With one or More Failures

##### MDD-Only

Four Tier 2 studies93-97 comparing psychotherapy to a control group were identified (Table 24). All indicated improvement with CBT. Only one of these studies received a good-quality rating.95,96 Two studies used an augmentation strategy,93,95,96 one used an unlimited strategy (patients in both groups may or may not start a new medication),97 and the fourth study used a combination strategy with patients in all groups starting a new medication;94the type of treatment strategy produced no clear variation in outcome. The presence of treatment failure in the current episode did not clearly influence outcome. The duration of the trials (all 16–20 weeks) did not vary. Groups in all studies were moderately depressed.

Table 24 Efficacy of psychotherapy versus control: Tiers 1-3

Author, Year Endpoint Current Episode Failure Requirement Quality | Intervention and Sample Size Study Details | Population Characteristics | Change in Depressive Symptoms | Response Remission
Harley, 2008^93^ 16 weeks, completers analysis Tier 2: Failure not required in current episode Fair | CBT [DBT] (n = 13) 16 sessions of dialectical behavior therapy skill training Control (n = 11) Waitlist Treatment strategy Augmentation Definitions Remission definition: HAM-D_17_ score ≤ 7 | Mean number of failed antidepressant trials: CBT: NR Control: NR Baseline Depression HAM-D_17_, mean (SD) CBT: 16.15 (4.47) Control: 18.64 (4.72) | HAM-D_17_* Change, mean (SD) CBT: -5.6 Control: -1.78 P < 0.05 * results based on completers (CBT: n = 10, Control: n = 9) | HAM-D_17_ Remission (%) CBT: 3 (23.1) Control: 0 (0) P = NR
Kocsis et al., 2010^94^ 12 weeks, completers analysis Tier 2: Required failure in the current episode Fair | CBASP (n=200) 16 to 20 sessions of cognitive behavioral analysis system of psychotherapy BSP (n=195) 16 to 20 sessions of brief supportive psychotherapy No Psychotherapy (n=96) Treatment strategy Combination (all patients received next option on pharamcotherapy algorithm including sertraline, escitalopram, buproprion, venlafaxine, mirtazapine, and lithium) Definitions Remission HAM-D_24_ < 8 AND 50% decrease from baseline | Number of failed antidepressant trials: Mean (SD) CBASP: NR BSP: NR No therapy: NR Baseline Depression: HAM-D_24_, mean (SD) CBASP: 19.52 (8.56) BSP: 19.44 (8.31) No therapy: 18.37 (8.00) | HAM-D_24_ Change*, mean (SD) CBASP: -8.23 BSP: -6.67 No therapy: -6.09 P = NS *based on completers CBASP n= 174 BSP n = 168 No therapy n = 76 | HAM-D_24_ Remission, n (%)* CBASP: 67 (33.5) BSP: 52 (26.7) No therapy: 30 (31.3) P = NS
Paykel, 1999^95^ and Scott, 2000^96^ 20 weeks Tier 2: Required failure in the current episode Good | CBT (n = 80) 16 sessions of cognitive therapy plus clinical management CM (n = 78) Clinical management alone Treatment strategy Primarily augmentation with minor medication dose adjustments allowed. Definitions Remission definition: HAM-D_17_ score ≤ 7 at 2 consectutive ratings 4 weeks apart | Mean number of failed antidepressant trials: CBT: NR CM: NR Baseline Depression HAM-D_17_, mean (SD) CBT: 12.2 (2.9) CM: 12.1 (2.7) | HAM-D_17_ Change, mean (SD) CBT: -3.4 CM: -2.8 P = NS | HAM-D_17_ Remission, n (%) CBT: 19 (24) CM: 10 (13) Hazard Ratio for remission 2.42 (95% CI: 1.08 to 5.45), P = 0.03
Wiles et al., 2008^97^ 4 months Tier 2: Required failure in the current episode Fair | CBT plus CM (n = 14) 12-20 sessions of cognitive behavioral therapy and clinical management CM (n = 11) Clinical management, no restrictions Treatment Strategy Unlimited | Mean number of failed antidepressant trials: CBT: NR CM: NR Baseline Depression BDI, mean (SD) CBT: 31.1 (8.5) CM: 26.8 (6.8) | BDI CBT scores decreased by an average of 11.2 points more than CM (95% CI, -19.3 to - 3.1) | BDI Response, n (%) CBT: 8 (57.1) CM: 0 (0.0) P = NR

BDI = Beck Depression Inventory; BSP = Brief Supportive Therapy; CBASP = Cognitive Behavioral Analysis System of Psychotherapy; CBT = cognitive behavioral therapy; CI = confidence interval; CM = clinical management; DBT = Dialectical Behavioral Therapy; HAM-D_17_ = 17-item Hamilton Depression Scale; n = number; NR = not reported; NS = not significant; P = p-value; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation

One good 20-week RCT (described in 2 articles) compared 16 sessions of cognitive therapy and clinical management (CM) (n = 80 patients) to CM alone (n = 78 patients).95,96 In each case, CM consisted of a visit with a psychiatrist every 4 weeks with minor medication adjustments to an antidepressant medication regimen allowed. Patients entered the study having residual depressive symptoms (HAM-D_17_ ≥ 8) despite having received greater than 4 weeks of adequate antidepressant treatment. Depression in both groups was mild (mean HAM-D_17_ for the two groups was 12.1-12.2). In an ITT analysis, there was no difference in the mean decrease in depressive severity (CBT plus CM -3.4 vs. CM alone -2.8, P = NS). Remission was defined more stringently as a HAM-D_17_ score ≤ 7 at two consecutive visits 4 weeks apart; using this definition, remission rates were greater for CBT plus CM when compared with CM alone (24% vs. 13%, P < 0.05).

One trial compared a 4-month treatment of CBT plus CM (n = 14 patients) to CM alone (n = 11 patients).97 Mean depressive severity at baseline as measured by the BDI was 31.1 for CBT plus CM versus 26.8 for CM, consistent with depression that was moderate to severe. Usual care (UC) in each group resulted in unlimited medication strategy. In an ITT analysis, the CBT plus UC group reduced depressive severity as measured by the BDI by an average of 11.2 points more than the UC group (95% CI, -19.3 to -3.1). Also, the CBT plus UC group had eight patients meeting response criterion, compared to none in the UC group.

One 12-week RCT compared 12 weeks of CBT plus pharmacotherapy (n = 200) with participants receiving pharmacotherapy alone (n = 96).94 A third arm assessing Brief Supportive Therapy was included in the study but is not an intervention of interest for this report and is therefore not included in this description. Enrolled patients were required to have an inadequate response (i.e., HAM-D_24_ ≥ 8) to their medication at baseline. At baseline patients had mild to moderate depression (HAM-D_24_, mean [SD]: CBT 19.5 [8.6], no CBT (medication only): 18.37 [8.0]). The trial used a combination treatment strategy, starting patients in all groups on a new medication. In a completers analysis, no significant differences were found between groups for decrease in depressive severity or rates of remission.

One 4-month trial compared a distinct form of CBT that involves both group and individual treatments called Dialectical Behavioral Therapy (DBT) (n = 13 patients) to a wait list control (n = 11).93 The two participating groups had moderate depressive severity at study enrollment (HAM-D_17_ scores averaged 16.15 for DBT group and 18.64 for waitlist control). In a treatment completer analysis at 4 months, the DBT group (n = 10) had a greater decrease in depressive severity than the waitlist group (n = 9) (-5.6 vs. -1.78, P < 0.05) and were more likely to achieve remission (23.1% vs. 0%).

We did not quantitatively synthesize these results.

##### MDD/Bipolar

There were no eligible studies.

#### Tier 3: Patients With Probable TRD

There were no eligible studies.

#### Tiers 1-3: Combined Results

Four Tier 2 studies comparing psychotherapy to a control group were identified. One good study reported in two articles95,96 and two fair studies93,97 supported greater outcomes for patients in psychotherapy compared to a control group. A fourth study, also in a Tier 2 MDD-only population, found no differences between groups for decrease in depressive severity or remission.94 Unlike the first three studies,93,95-97 the fourth study used a combination strategy and started all patients on a new antidepressant at the beginning.94 Two of the studies used augmentation strategies93,95,96 and another did not limit the pharmacotherapy strategies of participants.97 With only four studies identified for this comparison, it is difficult to determine how study design, participant, or treatment characteristics may have affected treatment efficacy. All four studies fell into Tier 2 and three of the trials94-97 required a failure in the current episode. All patients had MDD. Duration and method of psychotherapeutic interventions were similar across studies.

## Key Question 1b Comparisons Involving Pharmacologic Interventions for Acute Phase Treatment—Overview of Comparisons

In this section, we assess how nonpharmacologic treatments compare with pharmacological treatments in efficacy or effectiveness in treating acute-phase depressive symptoms in patients with TRD; these comparisons can help place nonpharmacologic treatments for TRD within the context of pharmacologic ones. First, we review the literature that directly compares nonpharmacologic and pharmacologic interventions for TRD, using the same approach we did in KQ 1a: categorizing first by intervention comparison, next by tier, and then by MDD versus the MDD/bipolar mix, while considering the role of the same key elements on treatment outcome.

For nonpharmacologic versus pharmacologic comparisons, we identified three studies. One study compared ECT versus pharmacotherapy, and two compared CBT with pharmacotherapy. Only one of these studies involved a TRD (Tier 1) population; enrolling an MDD/bipolar mix sample, it provided data showing that switching to ECT provided a greater decrease in depressive severity than switching to a new pharmacotherapy.66

Considering Tier 2 studies added two trials comparing CBT versus pharmacotherapy, both in MDD-only populations.101,102 These two studies involved moderately depressed groups and provided data showing that CBT was no different than medication treatments for a variety of treatment strategies.101,102 We could not make any conclusions about the impact of tier definition, diagnosis, depressive severity, treatment strategy, treatment characteristics, or treatment failure in the current episode.

For pharmacologic versus pharmacologic treatments, we identified nine trials that used a variety of pharmacologic treatment strategies to treat TRD including switching to a new antidepressant medication103-108 and augmenting the current medication.109-111 All involved patients who were severely depressed. Response rates for the pharmacologic options did not clearly differ from CBT, but two studies reporting CBT outcomes versus medications did appear to have poorer outcomes than ECT in one study. Finally, mean remission rates for pharmacologic options were similar to those reported in nonpharmacologic studies.

## Key Question 1b Comparisons Involving Pharmacologic Interventions for Acute Phase Treatment—Overview of Nonpharmacologic Versus Pharmacologic Treatments

Only three studies providing nonpharmacologic versus pharmacologic treatments were available (Table 25).66,101,102 Having such a limited database prevented a consideration of the effect on outcome of which tier of evidence was used, whether the population was MDD-only versus MDD/bipolar mix, the degree of depressive severity, the type of treatment strategy, the type of treatment characteristics, and whether the treatment failure was in the current episode.

Table 25 Number of good- and fair-quality studies by comparison, tier, and diagnostic mix for KQ 1b

Comparison | Tier | MDD-only | MDD and Bipolar Disorder
ECT versus pharmacotherapy | Tier 1 (≥ 2 treatment failures) | 0 | 1
Psychotherapy vs. pharmacotherapy | Tier 2 (≥ 1 treatment failures) | 2 | 0

ECT = electroconvulsive therapy

Strength of evidence assessments were made for three outcomes: change in depressive severity, response rates, and remission rates. We first will present the strength of evidence for Tier 1 studies alone, and then present strength of evidence for all three tiers considered together. When possible, within each comparison we report results by treatment strategy since this is a fundamental aspect of the antidepressant therapy.

A single MDD/bipolar mix study66 suggested better outcomes for ECT compared with pharmacologic treatment. Two studies found no difference between CBT and pharmacologic options.101,102

### Strength of Evidence: Tier 1 (TRD)

Only one study providing nonpharmacologic versus pharmacologic treatments was available.66 Having such limitations prevented consideration of the effect on outcome whether the population was MDD versus MDD/bipolar mix, the degree of depressive severity, the type of treatment strategy, the type of treatment characteristics, and whether the treatment failure was in the current episode.

Data were available to allow strength of evidence assessments for two outcomes: change in depressive severity and response rates (Table 26). This single trial provided low strength of evidence that ECT produced better outcomes than medications in a Tier 1 MDD/bipolar mix population; the study did not address remission rates.66

Table 26 Strength of Evidence: ECT versus pharmacotherapy

Comparison | Number of Studies; Subjects | Risk of bias Design/Quality | Consistency | Directness | Precision | Results and Strength of Evidence
Change in depressive severity | 1; 39 | Medium/High RCT 1 fair | Unknown | Direct | Imprecise | ECT > pharmacotherapy (paroxetine) Low
Response | 1; 39 | Medium/High RCT 1 fair | Unknown | Direct | Imprecise | ECT > pharmacotherapy (paroxetine). Low
Remission | 0; 0 | — | — | — | — | —

ECT = electroconvulsive therapy; RCT = randomized controlled trial

## Key Question 1b Comparisons Involving Pharmacologic Interventions for Acute Phase Treatment—Key Points of Nonpharmacologic Versus Pharmacologic Treatments

Only four trials provided a direct comparison of nonpharmacologic and pharmacologic treatment for TRD. The limited number of comparisons prevented any firm conclusions regarding the effect on outcome of the tier level of evidence used, whether the population was MDD-only versus MDD/bipolar mix, the degree of depressive severity, the type of treatment strategy, the type of treatment characteristics, or whether the treatment failure was in the current episode.

### Electroconvulsive Therapy Versus Pharmacotherapy

One Tier 1 study comparing ECT with pharmacotherapy found a greater change in depressive severity and a higher rate of response for participants in the ECT group.66

### Cognitive Behavioral Therapy Versus Pharmacotherapy

One Tier 2 study comparing CBT with pharmacotherapy found no differences in change in depressive severity, rate of response, or rate of remission between groups.101 A second study, with a small sample (N = 13), showed a difference in change in depressive severity but did not report the test of statistical significance.102

## Key Question 1b Comparisons Involving Pharmacologic Interventions for Acute Phase Treatment—Detailed Analysis of Nonpharmacologic Versus Pharmacologic Treatments

### Electroconvulsive Therapy Versus Pharmacotherapy

#### Tier 1: Patients With two or More Treatment Failures

One study comparing ECT to pharmacotherapy in an MDD/bipolar mix population was identified for Tier 1 (Table 27), finding greater improvement in severity and response for patients receiving ECT versus paroxetine.

Table 27 Efficacy of ECT versus pharmacotherapy: Tier 1

Author, year Endpoint Current Episode Failure Requirement Quality | Intervention and Sample Size Study Details | Population Characteristics | Change in Depressive Symptoms | Response Remission
Folkerts et al., 1997^66^ End of study phase (2-4 weeks), per protocol analysis Tier 1: Did not require failure in the current episode Fair | ECT (n = 21*) Right unilateral, mean txts = 7.2 sessions (2-3 weeks) Pharmacotherapy (n = 18*) Paroxetine 40 mg (max 50 mg/d, mean 44 mg/day) *per protocol Treatment Strategy Switch | Diagnosis Bipolar (%) ECT: 9.5 Pharm: 16.7 Mean number of failed antidepressant trials: ECT: 4.9 Pharm: 4.3 Baseline Depression HAM-D_21_, mean (SD) ECT: 31.1 (4.9) Pharm: 32.6 (5.4) | HAM-D_21_ Change, mean (SD) ECT: -18.6 Pharm: -9.6 P = 0.001 | HAM-D_21_ Response, n (%) ECT: 15 (71.4) Pharm: 5 (27.8) P = 0.006

ECT = electroconvulsive therapy; ; HAM-D_21_ = 21-item Hamilton Depression Scale; max = maximum, mg = milligram; mg/d = milligram per day; n = number; P = p-value; pharm = pharmacotherapy; SD = standard deviation; txt(s) = treatment(s)

##### MDD-Only

There were no eligible studies.

##### MDD/Bipolar

One 4-week trial compared outcomes for right-sided unilateral ECT (n = 21 patients) with paroxetine (n = 18 patients, 22 randomized).66 All patients discontinued current antidepressant therapy, and patients in the paroxetine group initiated pharmacotherapy. In the ECT group, 9.5 percent of patients (n = 2) had bipolar illness; 16.7 percent (n = 3) had bipolar illness in the medication group. Patients were severely depressed (mean HAM-D_21_ scores were 31.1 in the ECT group (SD 4.9) and 32.8 (SD 5.4) in the pharmacotherapy group). The ECT group experienced a greater decrease in depressive severity (-18.6 vs. -9.6, P = 0.001) and a greater response rate (71.4% vs. 27.8%, P = 0.006) than the paroxetine group.

#### Tier 2: Patients With one or More Failures

There were no eligible studies.

#### Tier 3: Patients With Probable TRD

There were no eligible studies.

#### Tiers 1-3: Combined

Only one study comparing ECT to pharmacotherapy was identified;66 this study is described in the section above.

### Cognitive Behavioral Therapy Versus Pharmacotherapy

Two Tier 2 studies, both MDD-only, compared psychotherapy versus pharmacotherapy and are described in Table 28. Both studies required an antidepressant failure in the current episode and used mixed strategies with between-group differences. One study compared augmenting to switching; the second study required that patients randomized to psychotherapy discontinue medications and compared this group to those who continued their antidepressant medications. Studies were similar in duration so no comparison by study duration was made.

Table 28 Efficacy of psychotherapy versus pharmacotherapy: Tier 1

Author, year Endpoint Current Episode Failure Requirement Quality | Intervention and Sample Size Study Details | Population Characteristics | Change in Depressive Symptoms | Response Remission
Thase et al., 2007^101^ 12-14 weeks Required failure in the current episode Fair | Augmentation - Cognitive Therapy (n = 65) Continued citalopram and added CT (16 sessions in 12 weeks) Augmentation -Medication (n = 117) Citalopram plus buproprion SR or buspirone Switch - Cognitive Therapy (n = 36) Switch from citalopram to CT 16 sessions in 12 weeks Switch - Medication (n = 86) Switch from citalopram to sertraline, bupropion SR, or extended-release-XR Treatment strategy Mixed-between group differences Definitions Remission defined as QIDS-SR ≤ 5 | Mean number of failed antidepressant trials: Aug CT: NR Aug Med: NR Switch CT: NR Switch Med: NR Baseline Depression QIDS-SR, mean (SD) Aug CT: 11.9 (4.3) Aug Med: 12.0 (4.6) Switch CT: 11.2 (4.3) Switch Med: 12.1 (4.6) | QIDS-SR % Change, mean (SD) Aug CT: -29.8 (40.5) Aug Med: -28.3 (39.6) P = 0.8302 Switch CT: -15.6 (40.7) Switch Med: -17.2 (46.2) P = 0.9040 | QIDS-SR Response, n (%) Aug CT: 23 (35.4) Aug Med: 33 (28.2) P = 0.2493 Switch CT: 8 (22.2) Switch Med: 23 (26.7) P = 0.8390 Remission, n (%) Aug CT: 20 (30.8) Aug Med: 39 (33.3) P = 0.7803 Switch CT: 11 (30.6) Switch Med: 23 (26.7) P = 0.9032
Moore et al., 1997^102^ 4 months is closest to end of treatment, completers analysis Required failure in the current episode Fair | Cognitive Behavioral Therapy (n = 7) minimum of 4 txts 1st month, 2 txts 2nd month and 1 per month following Continued medication management (n = 6) Continued medication dose within recognized therapeutic theshold Treatment Strategy Mixed- between group differences | Mean number of failed antidepressant trials: CBT: NR Meds: NR Baseline Depression HAM-D_17_*, mean (SD) CBT: 18.6 (3.3) Meds: 18.3 (3.9) *Completers only (CBT n = 5, Meds n = 4) | HAM-D_17_ Change*, mean (SD) CBT: -7.6 Meds: +1.5 *Completers only P = NR | HAM-D_17_ Response: NR at end of txt Remission: NR at end of txt

CT = cognitive therapy; CBT = cognitive behavioral therapy; ; HAM-D_17_ = 17-item Hamilton Depression Scale; Meds = continued medication management; n = number; NR = not reported; P = p-value; QIDS-SR = Quick Inventory of Depressive Symptomatology-Self Report; SD = standard deviation; SR = sustained release; txt = treatment; XR = extended release

#### Tier 1: Patients With two or More Treatment Failures

There were no eligible studies.

#### Tier 2: Patients With one or More Treatment Failures

##### MDD-Only

One study used a randomization strategy that considered patient choice. Sixteen sessions of cognitive therapy were compared to medication treatment as either an augmentation strategy (each was added to citalopram treatment, respectively) or a switch strategy (changed to CT or a different medication treatment).101 Patients entering all arms were of moderate severity (QIDS-SR mean 11 to 12). Using an ITT analysis, no differences in percentage change in depressive symptomatology were found when comparing CT to medication in either the augmentation (-29.5% vs. -28.3%, P = 0.8302) or switch (-15.6% vs. -17.2%, P = 0.9040) strategy comparisons. For patients who received augmentation to their citalopram, the response rate did not differ for those to whom CT was added (n = 65 patients) versus those to whom medication was added (n = 117 patients) (35.4% vs. 28.2%, P = 0.2493). Similarly, the response rate did not differ between those who switched to CT (n = 36 patients) compared to those who switched to a different medication (n = 86 patients) (22.2% vs. 26.7%, P = 0.8390). As with change in severity and response, no differences between cognitive therapy and pharmacotherapy were found in remission between groups in the augmentation (P = 0.7803) or switch group comparisons (P = 0.9032).

One small study102 randomized patients to either switch to 4 months of CBT (n = 7) or continue their current medication management (n = 6). Enrolled patients had moderate depressive severity (mean HAM-D score at baseline 18.6 for CBT [SD 3.3] and 18.3 [SD 3.9] for medication). A limited treatment completer's analysis of acute phase outcomes at 4 months suggested a greater decrease in severity for the CBT group (-7.6 points [n = 5 patients] vs. +1.5 points [n = 4 patients], statistical analysis not reported).

##### MDD/Bipolar

There were no eligible studies.

#### Tier 3: Patients With Probable TRD

There were no eligible studies.

#### Tiers 1–3: Combined Results

Only two studies were identified for this comparison.101,102 Although one study did not find differences between groups in treatment efficacy (i.e., change in severity, response, and remission),101 the second study showed a difference in change in depressive severity but did not report the results of a test of statistical significance.102 Both studies were identified in Tier 2, required a failure in the current episode, included only patients with MDD, included samples with moderate depressive severity, and used similar treatment characteristics (i.e., both used cognitive behavioral therapy and were approximately 4 months in duration). The first study compared treatment arms that augmented with either psychotherapy or a new antidepressant medication and arms that switched to psychotherapy or a new antidepressant.101 The second study compared switching to psychotherapy to continued medication management.102

## Key Question 1b Pharmacologic Interventions for Acute Phase Treatment—Overview of Pharmacologic Versus Pharmacologic Treatments

All studies reviewed in this section are RCTs that involve Tier 1 TRD (≥ 2 failures of adequate antidepressant trials) and MDD-only patients. This synthesis allows a crude comparison between what one might expect as a “next-step” pharmacologic intervention relative to a next-step nonpharmacologic intervention. Consequently, these studies may provide a reference for the degree of response (or remission) that one could expect from a next-step pharmacologic treatment (relative to a next-step nonpharmacologic treatment).

Some of these studies include a group that did not receive an active primary antidepressant treatment (e.g., olanzapine, which by itself is not used as an antidepressant); these arms will not be considered in the subsequent analyses. We focus instead on the same three outcomes addressed in previous sections—change in depressive severity, response rate, and remission rate. However, we will not formally assess strength of evidence as we did in the prior sections. Rather, we will present the available clinical response data that illustrate what is expected following an active antidepressant treatment. We will consider both responses seen after a change in pharmacologic treatment (either a switch or augmentation) and responses seen after maintenance on the same pharmacologic management without a change in treatment. Finally, also in contrast to our prior sections, we will not consider the role of MDD/bipolar mix or tier definition, as these variables are by definition fixed in this section, but we will attempt to consider the other key elements.

We identified 12 Tier 1 MDD-only studies involving moderately to severely depressed groups that compared pharmacologic treatment as a next treatment step (Table 29).103-114 We attempted to determine mean effect sizes, relative risks of response, and relative risks of remission for pharmacologic versus control studies to allow a comparison with similar outcomes in the nonpharmacologic versus control trials (KQ 1a, indirect). However, there were no comparable, common control groups not receiving a mood-related medication to allow such comparisons. Instead, we determined mean average outcomes for pharmacologic treatments. Although we were unable to statistically compare these outcomes, there was broad overlap in their decreases in depressive severity, relative risks of response, and relative risks of remission.

Table 29 Number of good- and fair-quality studies by comparison and definition of treatment resistance (tier) for MDD-only for KQ 1b

Comparison | Tier | MDD-Only | MDD and Bipolar Disorder
Pharmacotherapy versus Pharmacotherapy | Tier 1 (≥ 2 treatment failures) | 12 | NA
Pharmacotherapy versus Pharmacotherapy | Tier 2 (≥ 1 treatment failures) | NA | NA
Pharmacotherapy versus Pharmacotherapy | Tier 3 (probable treatment failure) | NA | NA

MDD = major depressive disorder; NA = not applicable

## Key Question 1b Pharmacologic Interventions for Acute Phase Treatment—Key Points of Direct Comparisons

All studies included in the pharmacologic intervention versus pharmacologic intervention were conducted in patients with MDD-only TRD. We identified 12 studies: 7 studies primarily tested switch strategies103-108,112 and 5 assessed augmentation.109-111,113,114 Seven of the 12 studies also included a maintenance arm, allowing further analysis of this strategy as well. To allow comparison to the nonpharmacological interventions, weighted means were calculated for each strategy for the three outcomes of interest.

Regarding changes in depressive severity, mean changes in MADRS scores were similar across the three strategies (switch -11.2 [95% CI, -14.7 to -7.8], augmentation -11.2 [95% CI, -13.7 to -8.8], and maintenance -7.6 [95% CI, -9.2 to -5.2]). Consistent results were seen for response and remission rates (switch 39.8% [95% CI, 30.7-48.9] and 22.3% [95% CI, 16.2-28.4], augmentation 38.1% [95% CI, 31.0-45.3] and 27.2% [95% CI, 20.4-34.0], maintenance 27.3% [95% CI, 19.8-34.8] and 16.8% [95% CI, 13.5-20.2], respectively). These data are limited by the combination of different types of antidepressants and augmenting options included in this analysis.

Only one study did not require a failure in the current episode110 limiting further analysis by this variable. Though some variability in the depressive severity of populations was present, differences by severity were not apparent.

## Key Question 1b Pharmacologic Interventions for Acute Phase Treatment—Detailed Analysis of Direct Comparisons

### Tier 1: Patients With two or More Treatment Failures

Twelve studies were identified for this population. Seven of the studies used switch strategies103-108,112 and five tested an augmentation strategy.109-111,113,114

#### Switching Strategies

Seven studies testing a switch strategy were identified and are described in Table 30.^103-108,112^ One study compared the 12-week outcomes for patients who failed venlafaxine treatment and were randomized to one of five groups: a combination of olanzapine (either 6 or 12 mg/day)/fluoxetine (either 25 or 50 mg/day) (n = 243 patients, pooled from 4 groups), olanzapine alone (either 6 or 12 mg/day) (n = 62 patients), fluoxetine alone (either 25 or 50 mg/day) (n = 60 patients), a “pseudo placebo” low-dose combination of olanzapine (1mg/day) and fluoxetine (5 mg/day) (n = 59 patients), or continuing with venlafaxine alone (75-375 mg/day) (n = 59 patients).103 Only one treatment failure was required in the current episode (failure to respond to venlafaxine). Baseline depressive severity for the overall sample was in the moderate-to-severe range (MADRS 30.0). An ITT analysis favored the olanzapine/fluoxetine combination versus fluoxetine alone in all depression outcome comparisons, but showed no difference between any of the other groups. The combination was better than fluoxetine alone for greater change in depressive severity (-14.06 vs. -7.71, P < 0.001; other severity changes ranged from -11.7 to -13.73), greater response rate (43.3% vs. 25.4%, P = 0.017; other response rates ranged from 33.9% to 50.0%) and greater remission rate (29.9% vs. 13.8%, P = 0.013; other remission rates ranged from 17.9% to 22.4%).

Table 30 Efficacy of pharmacotherapy versus pharmacotherapy, switching strategies: Tier 1

Author, year Endpoint Current Episode Failure Requirement Quality | Intervention and Sample Size Study Details | Population Characteristics | | Change in Depressive Symptoms | Response Remission
Corya et al., 2006^103^ 12 weeks Required failure in the current episode Fair | OLA-FLU (n = 243) Combined 4 groups OLA (n = 62) 6 or 12mg/d FLU (n = 60) 25 or 50 mg/d VEN (n = 59) 75-375mg/d LD OLA plus FLU (n = 59) 1mg/d OLA, 5mg FLU Treatment strategy OLA-FLU: Switch OLA: Not of interest FLU: Switch VEN: Maintenance LD OLA-FLU: Switch Definitions Remission defined as MADRS ≤ 8 at two consecutive visits | Baseline Depression MADRS, mean (SD) Overall: 30.0 (6.8) | | MADRS Change, mean (SD) OLA-FLU: -14.06 (0.59) OLA: -7.71 (1.17) FLU: -11.70 (1.14) VEN: -13.73 (1.16) LD OLA-FLU: -11.97 (1.13) OLA-FLU versusOLA P < 0.001 all others NS | MADRS Response, n (%) OLA-FLU: 100 (43.3) OLA: 15 (25.4) FLU: 19 (33.9) VEN: 29 (50.0) LD OLA-FLU: 20 (36.4) OLA-FLU versus OLA, P = 0.017 All others NS Remission, n (%) OLA-FLU: 69 (29.9) OLA: 8 (13.8) FLU: 10 (17.9) VEN: 13 (22.4) LD OLA-FLU: 11 (20.0) OLA-FLU versus OLA, P = 0.013. All others NS
Fang et al., 2010^112^ 8 weeks, ITT Required failure in the current episode Fair | MIR (n = 55) 45mg/day PAR (n = 45) 20 mg/day VEN (n = 50) 225mg/day Treatment strategy MIR: Switch PAR: Switch VEN: Switch Definitions Remission: HAM-D_17_ ≤ 7 | Baseline Depression HAM-D_17_, mean (SD) Overall: 24.6 (5.8) | | HAM-D_17_ Change, mean (SD) NR | HAM-D_17_ Response, n (%) MIR: 32 (58.2) PAR: 30 (66.7) VEN: 32 (64.0) P = 0.664 Remission, n (%) MIR: 20 (36.4) PAR: 21 (46.7) VEN: 21 (42.0) P = 0.578
Fava et al., 2006^104^ 14 weeks Required failure in the current episode Good | MIR (n = 114) Up to 60 mg/d NOR, (n = 121) Up to 200 mg/d Treatment strategy MIR: Switch NOR: Switch Definitions Remission defined as HAM-D_17_ ≤ 7 | Baseline Depression HAM-D_17_, mean (SD) MIR: 19.8 (7.0) NOR: 18.6 (5.9) | | HAM-D_17_ Change: NR | HAM-D_17_ Remission, n MIR:14 (12.3) NOR: 24 (19.8) P = 0.27
Mazeh et al., 2007^105^ 6 weeks* only in the elderly Required failure in the current episode Fair | PAR (n = 15) 10-60 mg/d, mean = 26mg/d VEN (n = 15) 75-300 mg/d, mean = 165mg/d Treatment strategy PAR: Switch VEN: Switch Definitions Remission defined as HAM-D_21_ ≤ 7 | Baseline Depression HAM-D_21_, mean (SD) PAR: 30.1 (7.9) VEN: 26.3 (5.9) | | HAM-D_21_ Change, mean (SD) PAR: -12.5 VEN: -19.1 P < 0.0003 | HAM-D_21_ Response, n (%) PAR: 8 (53) VEN: 12 (80) P = NR Remission, n (%) PAR: 5 (33) VEN: 9 (60) P = NR
McGrath et al., 2006^106^ 12 weeks Required failure in the current episode Good | TRAN (n = 58) 10 mg/d for 2wk, weekly increases of 10 mg/d until intolerance or 60 mg/dmaximum VEN ER plus MIR (n = 51) VEN - 37.5mg/d week 1, 75mg/d week 2, 150 mg/day weeks 3-5, 225 mg/d weeks 6-8, 300 mg/dthereafter MIR—15mg/d weeks 1-2, 30 mg/d next 8 weeks, 45mg/d thereafter Treatment strategy TRAN: Switch VEN-MIR: Switch Definitions Remission defined as HAM-D_21_ ≤ 7 | Baseline Depression HAM-D_17_, mean (SD) TRAN: 19.6 (7.6) VEN-MIR: 19.7 (5.5) | | HAM-D_17_ Change: NR | HAM-D_17_ Remission, n (%) TRAN: 4 (6.9) VEN-MIR: 7 (13.7) P = NS
Poirier and Boyer, 1999^107^ 4 weeks Required failure in the current episode Fair | VEN (n = 61) 37.5mg/twice day, increased to 200 - 300 mg/d PAR (n = 62) initiated at 20 mg/day and increased to 30—40 mg/d Treatment strategy VEN: Switch PAR: Switch Definitions Remission defined as HAM-D_17_ < 10 | Baseline Depression HAM-D_17_, mean (SD) VEN: 24.6 (3.9) PAR: 24.5 (4.1) | | HAM-D_17_ Change*, mean (SD) VEN: -11.1 (8.5) PAR: -10.2 (6.8) P = 0.55 ITT, P = 0.70 *N observed (VEN: 52, PAR: 55) | HAM-D_17_ Response, n VEN: 27 (44.3) PAR: 18 (29.0) ITT, P = 0.07 Remission, n VEN: 22 (36.1) PAR: 11 (17.7) ITT, P = 0.02
Shelton et al., 2005^108^ 8 weeks Did not require failure in the current episode Good | OLA-FLU combination (n = 146) 6 mg/d OLA plus 25mg/d FLU or 12mg/d OLA plus 50 mg/d FLU OLA (n = 144) 6-12mg/d FLU (n = 142) 25 to 50 mg/d NOR, (n = 68) Max dose 175mg/d Treatment strategy OLA+FLU: Switch OLA: Not of interest FLU: Switch NOR: Maintenance | Baseline Depression MADRS, mean (SD) OLA-FLU: 28.5 (7.5) OLA: 28.4 (7.3) FLU: 28.4 (7.3) NOR: 28.8 (6.5) | MADRS Change, mean (SE) OLA-FLU: -8.71 (0.70) OLA: -6.95 (0.71) FLU: -8.51 (0.70) NOR: -7.46 (0.98 FLU versus OLA-FLU, P = 0.841 OLA versus OLA-FLU, P = 0.77 | | MADRS Response, n (%) OLA-FLU: 40 (27.5) OLA: 27 (19.3) FLU: 41 (28.9) NOR: 20 (30.3) P = 0.18 Remission, n (%) OLA-FLU: 24 (16.9) OLA: 18 (12.9) FLU: 18 (13.3) NOR: 12 (18.2) P = 0.62

FLU = fluoxetine; HAM-D_17_ = 17-item Hamilton Depression Scale; HAM-D_21_ = 21-item Hamilton Depression Scale; ER = extended release; ITT = intention to treat; LD = low-dose; OLA = olanzapine; MADRS = Montgomery-Asberg Depression Rating Scale; mg/d = milligrams per day; MIR = mirzapine; n = number; NOR = nortiptyline; NR = not reported; NS = not significant; OLA-FLU = olanzapine/fluoxetine; PAR = paroxetine; SD = standard deviation; TRAN = tranylcypromine; VEN = venlafaxine; wk = week

A fair 8-week study compared switching to one of three antidepressants: mirtazapine (n = 55), paroxetine (n = 55), or venlafaxine (n = 50). Patients were required to have at least one treatment failure in the current episode and were severely depressed at baseline (mean HAM-D_17_ 24.6). In an ITT analysis, response and remission rates did not differ between groups.

A good-quality study lasting 12–14 weeks compared switching to mirtazapine (up to 60 mg/day; n = 114 patients) or nortriptyline (up to 200 mg/day; n = 121 patients) in a group of patients who had two adequate antidepressant treatment failures in the current episode.104 Enrolled patients were severely depressed at baseline (mean HAM-D_17_ 18-20). Response rates as measured by the QIDS-SR did not differ significantly (13.4% for mirtazapine vs. 16.5% for nortriptyline). Similarly, remission rates did not differ significantly between the mirtazapine and nortriptyline groups (12.3% vs. 19.8%, P = 0.27).

A 6-week study compared outcomes for patients 65 years and older who were randomized to receive venlafaxine (75 mg to 300 mg/day, mean daily dose 165 mg/day; n = 15 patients) or paroxetine (10-60 mg/day, mean 26 mg/day; n = 15 patients).105 Patients had two failures of adequate trials during the current episode and were severely depressed at study entry (mean HAM-D_21_ 26-30). In an ITT analysis, the decrease in depressive severity after 6 weeks was greater for venlafaxine than paroxetine (-19.1 vs. -12.5, P < 0.0003). Differences between response rates (80% vs. 53%, P = NR) and remission rates (60% vs. 33%) in this small sample was less clear.

One study compared 12-week outcomes for patients with treatment failure following three adequate antidepressant treatments in the current episode. Patients were randomized to tranylcypromine (10 mg to 60 mg/day) (n = 58 patients) or a combination of venlafaxine ER (37.5 mg to 300 mg/day) plus mirtazapine (15 to 45 mg/day) (n = 51 patients).106 Patients were severely depressed at study entry (mean HAM-D_17_ 19-20). Outcomes tended to favor the venlafaxine/mirtazapine combination, but not to a statistically significant degree. In an ITT analysis, response rates (as measured by the QIDS-SR) did not significantly differ (12.1% with tranylcypromine vs. 23.5% with venlafaxine plus mirtazapine), nor did the remission rates measured by HAM-D_17_ (6.9% vs. 13.7%).

Another venlafaine/paroxetine study compared 200–300 mg/day of venlafaxine (n = 61 patients) to 30–40 mg/day of paroxetine (n = 62 patients) for 4 weeks.105 Patients had treatment failure following two adequate treatments other than venlafaxine or paroxetine in the current episode. Enrolled patients were severely depressed at study entry (mean HAM-D_24-25_). The authors conducted an ITT analysis. The change in depressive severity did not differ between the two groups. However, the response rate tended to favor venlafaxine (44.3% vs. 29.0%, p = 0.07), and the remission rate supported venlafaxine over paroxetine (36.1% vs. 17.7%, P = 0.02).

Another olanzapine/fluoxetine switch study compared the 8-week outcomes for four groups following nortriptyline treatment failure: a combination of olanzapine (6 mg/day or 12 mg/day)/fluoxetine (25 mg/day or 50 mg/day) (n = 146 patients), olanzapine alone (6–12 mg/day) (n = 144 patients), fluoxetine alone (25–50 mg/day) (n = 142 patients), and continuing on nortriptyline alone (50–175 mg/day) (n = 68 patients).108 Only one treatment failure was required to be in the current episode (failure to respond to nortriptyline). Baseline depressive severity for each group averaged between 28 and 29 on the MADRS, consistent with moderate-to-severe depressive severity. A mixed-effects model repeated-measures regression showed no differences between the four groups in decrease in depressive severity (-8.71, -6.95, -8.51, and -7.46, respectively, P = NS), response rates (27.5%, 19.3%, 28.9%, and 30.3%, respectively, P = 0.18), or remission rates (16.9%, 12.9%, 13.3%, 18.2%, respectively, P = 0.62).

#### Augmenting Strategies

Five studies tested augmenting strategies and are described in Table 31.^109-111,113,114^ Two fair studies assessing the efficacy of augmenting with ariprprazole were identified.113,114 Patients in both studies had a failed antidepressant trial in the current episode with 2 or more failures overall and were moderately depressed at baseline (mean MADRS [SD]: study 1^113^: ARI 26.0 [6.1] placebo 25.9 [6.5]; study 2^114^ ARI 26.6 [5.8] placebo 27.1 [5.8]). In modified ITT analyses, both studies found significantly greater outcomes for ARI when compared with placebo across all three outcomes of interest.113,114

Table 31 Efficacy of pharmacotherapy versus control, augmenting strategies

Author, year Endpoint Current Episode Failure Requirement Quality | Intervention and Sample Size Study Details | Population Characteristics | Change in Depressive Symptoms | Response Remission
Berman et al., 2007^113^ 6 weeks, mITT Required failure in the current episode Fair | ARI (n = 184) Placebo (n = 178) Treatment strategy ARI: Augmentation Placebo: Maintenance All patients receiving ESC, FLU, PAR, SER, VEN at maximum tolerated dose; ARI (2-20 mg/day) Definitions Remission defined as MADRS < 10 and ≥ 50% decrease in score | Baseline Depression MADRS, mean (SD) ARI: 26.0 (6.1) Placebo: 25.9 (6.5) | MADRS Change*, mean (SD) ARI: -8.8 Placebo: -5.8 P < 0.001 *mITT ARI N = 181 Placebo: 172 | MADRS Response, n (%) ARI: 61 (33.2) Placebo: 41 (23.0) * P ≤ 0.05 Remission, n (%) ARI: 47 (25.5) Placebo: 27 (15.2) * P ≤ 0.01
Berman et al., 2009^114^ 6 weeks, mITT Required failure in the current episode Fair | ARI (n = 177) Placebo (n = 172) Same antidepressant medications as above Treatment strategy ARI: Augmentation Placebo: Maintenance All patients receiving ESC, FLU, PAR, SER, VEN at maximum tolerated dose; ARI (2-20 mg/day) Definitions Remission defined as MADRS < 10 and ≥ 50% decrease in score | Baseline Depression MADRS, mean (SD) ARI: 26.6 (5.8) Placebo: 27.1 (5.8) | MADRS Change*, mean (SD) ARI: -10.1 Placebo: -6.4 P < 0.001 *mITT ARI: N = 174 Placebo: N = 169 | MADRS Response, n (%) ARI: 81 (45.8) Placebo: 45 (26.2) * P ≤ 0.001 Remission, n ARI: 64 (36.2) Placebo: 32 (18.6) *P ≤ 0.001
Nierenberg et al., 2003^109^ 6 weeks Required failure in the current episode Fair | LITH Augmentation (n = 18) Dosing strategy NR Placebo (n = 17) All patients continued nortriptyline Treatment strategy LITH: Augmentation Placebo: Maintain | Baseline Depression HAM-D_21_, mean (SD) LITH: 18.8 Placebo: 19.8 | HAM-D_21_ Change, mean (SD) LITH: -2.9 Placebo: -3.6 P = NR | HAM-D_21_ Response, n (%) LITH: 2 (11.1) Placebo: 3 (17.6) P = NS
Shelton et al., 2001^110^ 8 weeks Required failure in the current episode Fair | OLA+ Placebo (n = 8) 5-20 mg/d FLU+ Placebo (n = 10) 20-60 mg/d OLA+FLU (n = 10) same dose as above Treatment strategy OLA+PLA: Not of interest FLU+PLA: Maintain OLA: Augmentation | Baseline Depression MADRS: NR | MADRS Change, mean (SD) OLA+ Placebo: -2.8 FLU+ Placebo: -1.2 OLA+FLU:-13.6 | MADRS Response, n (%) OLA+ Placebo: 0 (0) FLU+ Placebo: 1 (10) OLA+FLU: 6 (60) OLA-FLU versus OLA+ Placebo, P = 0.03 OLA+FLU versus FLU+ Placebo, P = 0.11
Thase et al., 2007^111^ 8 weeks Required failure in the current episode Fair | OLA+FLU (n = 200) OLA 6, 12, or 18 mg/day plus 50 mg/day FLU OLA (n = 206) 6, 12, or 18 mg/day FLU (n = 200) 50 mg/day Treatment strategy OLA-FLU: Augmentation OLA: Not of interest (Switch) FLU: Maintain | Baseline Depression MADRS, mean (SD) OLA+FLU: 30.0 (6.7) OLA: 29.9 (6.4) FLU: 29.9 (6.7) | MADRS Change, mean (SD) OLA+FLU: -12.6 (10.3) OLA: -9.2 (9.7) FLU: -8.9 (9.0) OLA+FLU versus OLA, P < 0.001 OLA+FLU versus FLU, P < 0.001 | MADRS Response, n (%) OLA+FLU: 80 (40.4) OLA: 60 (29.6) FLU: 51 (25.9) OLA+FLU versus FLU, P = 0.028 OLA+FLU versus FLU, P = 0.003 Remission, n (%) OLA+FLU: 54 (27.3) OLA: 34 (16.7) FLU: 29 (14.7) OLA+FLU versusFLU, P = 0.012 OLA-FLU versus FLU, P = 0.003

ARI = aripriprazole; ESC = escitalopram; FLU = fluoxetine; HAM-D_21_ = 21-item Hamilton Depression Scale; LITH = lithium, n = number; MADRS = Montgomery-Asberg Depression Rating Scale; mg/d = milligrams per day; mITT = modified intention to treat; NR = not reported; NS = not significant; OLA = olanzapine; OLA-FLU = olanzapine+fluoxetine; OLA+PLA = olanzapine plus placebo; PAR = paroxetine; SD = standard deviation; SER = sertraline; VEN = venlafaxine

Another study compared outcomes at 6 weeks for patients who had not responded to a 7-week nortriptyline trial and were assigned to augment nortriptyline with either lithium (dose not clarified; n = 18 patients) or placebo (n = 17 patients).109 Prior to their nortriptyline trial, they had at least one but no more than five treatment failures following antidepressant medication treatment during the current episode. Patients were moderately depressed at study entry (mean HAM-D_17-18_). In an ITT analysis, change in depressive severity did not differ between groups (-2.9 for lithium augmentation vs. -3.6 for placebo, P = 0.72). Similarly, response rates did not differ significantly for lithium augmentation versus placebo augmentation (11.1% vs. 17.6%, P = NS).

A third study compared outcomes at 8 weeks for patients who had two treatment failures to different classes of antidepressants and had an additional failed trial of fluoxetine in the current episode. These patients were assigned to either switch to olanzapine (5 to 20 mg/day; n = 8 patients), add olanzapine (5 to 20 mg/day) to fluoxetine (20 to 60 mg/day) (n = 10 patients) or continue with fluoxetine (50 mg/day) with placebo added (n = 10 patients).110 Baseline mean depressive severity was not reported. The olanzapine/fluoxetine augmentation group had a greater decrease in HAM-D_21_ items severity than either the olanzapine switch group (-11.7 vs. -5.9, P = 0.03) or the fluoxetine continuation group (-11.7 vs. -3.8, P = 0.07). The olanzapine/fluoxetine augmentation group also had a greater response rate than the olanzapine switch group (60% vs. 0%, P = 0.03) and a trend towards greater response than the fluoxetine continuation group (60% vs. 10%, P = 0.11).

Lastly, a study that consisted of two parallel, concurrent trials compared the 8-week outcomes of an olanzapine/fluoxetine combination (6, 12, or 18 mg olanzapine plus 50 mg/day of fluoxetine; n = 200 patients), olanzapine (6, 12, or 18 mg/day; n = 199 patients), or fluoxetine (50 mg/day; n = 206 patients).111 The pooled analyses are reported here. Treatment failure was in the current episode. Patients entering the study were moderately to severely depressed (MADRS score of approximately 30). ITT analyses at study end favored the combination treatment relative to the other two groups in each instance. The combination produced greater differences between groups in the decrease in depressive severity (-10.8 vs. -10.1 in olanzapine only, and vs. -9.4 in fluoxetine only, P < 0.001 in each instance); a greater response rate (40.4% vs. 25.9%, [P = 0.003] and vs. 29.6% [P = 0.028], respectively); and a greater remission rate (27.3% vs. 14.7% [P = 0.003] and versus 16.7% [P = 0.012], respectively).

### Synthesis of MDD Outcomes (Tier 1)

To provide information reporting average outcomes in pharmacologic trials of TRD, we calculated weighted means for the change in depressive severity, response rate, and remission rate (Table 32).

Table 32 Mean clinical outcomes for TRD (Tier 1) patients in pharmacologic studies

Clinical Outcome | Switching | Augmentation | Maintenance
Mean change HAM-D | -10.6 (-16.4 to -4.9) | No data | No data
Mean change MADRS | -11.2 (-14.7 to -7.8) | -11.2 (-13.7 to -8.8) | -7.6 (-9.2 to -5.2)
Mean response rates (HAM-D and MADRS) | 39.8% (30.7 to 48.9) | 38.1% (31.0 to 45.3) | 27.3% (19.8 to 34.8)
Mean remission rates (HAM-D and MADRS) | 22.3% (16.2 to 28.4) | 27.2% (20.4 to 34.0) | 16.8% (13.5 to 20.2)

HAM-D = Hamilton Rating Scale for Depression; MADRS = Montgomery-Asberg Depression Rating Scale

Note: Numbers in parenthesis indicate the 95 percent confidence interval

We quantitatively synthesized weighted means of the changes in depressive severity for studies involving the two interviewer-administered instruments, the HAM-D and MADRS. For patients switched to a new medication, the mean average change in HAM-D was -10.6 points, and the mean average change in studies using the MADRS was -11.2. For patients receiving medication augmentation, the mean change in depressive severity was -11.2 on the MADRS. We also identified seven measures of depressive severity change in patients who continued on their same medication without a change in treatment. Those measured by MADRS showed a mean change of -7.6, with confidence intervals overlapping with switching and augmentation results.

For changes in response rates, results varied greatly, with response rates ranging from 12.1 to 80 percent. The two highest response rates were from a study restricted to an elderly population,105 a sample distinct from the others. A weighted mean response rate for switch strategies was 39.8 percent. Considering augmentation strategies provided seven more measures, ranging from 11.1 percent to 45.8 percent. A quantitative synthesis of these rates suggests an average response rate of 38.1 percent for TRD patients following an augmentation next-step pharmacologic treatment. For those who maintained on their pharmacologic treatment, we identified five measures of response rates, which ranged from 10 percent to 50 percent. The weighted mean average response rate for maintenance treatment was 27.3 percent.

Finally, for changes in remission rates, we identified measures involving switch strategies that were not restricted to the elderly population. These remission rates ranged from 6.9 percent to 46.7 percent, with a weighted mean average remission rate of 22.3 percent for TRD patients following a switch to a next-step pharmacologic treatment. Five studies with augmentation arms provided five augmentation measures of remission rates, ranging from 15.2 percent to 29.9 percent, with a weighted mean average remission rate of 27.2 percent. For those who maintained on their pharmacologic treatment, measures of remission showed rates varying from 14.7 percent to 22.4 percent, with a weighted mean average remission rate of 16.8 percent.

## Key Question 2 Efficacy or Effectiveness for Maintaining Remission or Treating Patients With Unresponsive or Recurrent Disease: Overview

As with KQ 1, KQ 2 addressed direct or indirect comparisons of the four nonpharmacological interventions (ECT, rTMS, VNS, and either CBT or IPT). Unlike KQ 1, however, we did not include studies that compared pharmacologic interventions. In the detailed analysis section below, first we present the studies by comparison, then by tier, and then by whether the population involves MDD-only patients or an MDD/bipolar mix. Information is presented for the three tiers used in KQ 1 (Tier 1, two or more treatment failures; Tier 2, one or more treatment failures, but not including the studies in Tier 1; and Tier 3, “probable” treatment resistance). Again, only studies with quality ratings of good or fair are featured.

We identified a total of 11 studies addressing maintenance of remission using nonpharmacologic interventions (Table 33). Two Tier 1 studies, reported in three articles, compared rTMS versus sham in an MDD-only population, with both indicating that rTMS was superior to sham in preventing relapse.69,77,99 However, these trials included very few patients in the relapse prevention phase. A third Tier 1 study compared rTMS with sham in an MDD/bipolar mix population. Differences between rTMS and sham were not statistically significant at 1- and 3-months followup.82

Table 33 Number of studies included by comparison and definition of treatment resistance (tier) for KQ 2

Comparison | Tier | MDD-Only | MDD and Bipolar Disorder
rTMS vs. sham | Tier 1: ≥ 2 treatment failures | 2 | 1
rTMS vs. sham | Tier2: ≥ 1 treatment failure | 2 additional | 1 additional
rTMS vs. sham | Tier 3: Probable | 0 | 1 additional
ECT vs. rTMS | Tier 3: Probable | 1 additional | 2 additional
CBT vs. usual care | Tier 3: Probable | 1 additional | 0

CBT = cognitive behavioral therapy; ECT = electroconvulsive therapy; MDD = major depressive disorder; rTMS = repetitive transcranial magnetic stimulation; vs. = versus.

Tier 2 evidence added three trials comparing rTMS versus sham. Two of these trials involved MDD-only patients (five articles).86,87,115,116 One study involved an MDD/bipolar mix population.88 All three trials supported benefit of rTMS over sham in maintaining remission.

Tier 3 evidence added five studies. One study compared rTMS versus sham in an MDD/bipolar mix population, finding benefit again for rTMS over sham.90 Three studies provided the only head-to-head comparison available, comparing ECT versus rTMS, one in an MDD-only population that was reported in two articles117,118 and two in an MDD/bipolar mix population that was reported in four articles.60-63 All studies indicated no difference in maintaining remission at 7 weeks to 6 months followup.

Most studies either allowed patients to continue antidepressants throughout the trial or required that they be given an antidepressant following the active nonpharmacological treatment. The duration of followup for assessing maintenance of remission ranged from 2 weeks to nearly 1 year. The method for assessing maintenance of remission varied among trials. Some trials followed (or randomized) only patients who had achieved a response or remission during active treatment and then measured relapse during a post-treatment period. Other trials followed all randomized participants during a post-treatment period regardless of response or remission with initial treatment. These trials generally reported the number of patients in remission at the end of treatment and at the end of followup, which provides an indirect measure of maintenance of remission.

### Strength of Evidence: Tier 1

There were no Tier 1 direct (head-to-head) comparisons available. The single comparison involving a Tier 1 TRD population was rTMS versus sham; three studies provided insufficient evidence to draw a conclusion (Table 34). Studies found that relapse rates do not differ significantly between rTMS and sham, however, too few patients were followed during the continuation phases of these two studies and patients in the third received a co-intervention, providing insufficient evidence to allow for a conclusion.

Table 34 Strength of Evidence: maintenance of remission of rTMS versus sham – Tier 1

Comparison | Number of studies; subjects^*^ | Risk of bias Design/Quality | Consistency | Directness | Precision | Results and Strength of Evidence
rTMS vs. sham | 3; 46 | High 3 RCTs Fair | Inconsistent | Indirect | Imprecise | No significant differences in maintenance of remission Insufficient

* Number of subjects reflects only those followed past acute treatment

RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; vs. = versus

## Key Question 2 Efficacy or Effectiveness for Maintaining Remission or Treating Patients With Unresponsive or Recurrent Disease: Key Points

Only limited evidence addressed maintenance of remission among MDD patients. These included the following interventions: ECT (2 studies), rTMS (10 studies, including ECT in three head-to-head trials), and CBT (1 study). No studies assessing maintenance of remission directly compared ECT, rTMS, VNS, and CBT in patients in a TRD (Tier 1) population. No evidence was identified for VNS. The only evidence for TRD (Tier 1) compared rTMS versus sham.

### Electroconvulsive Therapy Versus Repetitive Transcranial Magnetic Stimulation

No TRD (Tier 1) data were available for this comparison, but three trials provided direct Tier 3 evidence. One trial in an MDD-only population, reported in two articles, found no statistically significant differences in relapse rates at 3 months and 6 months after treatment ended.117,118 A second trial in an MDD/bipolar mix population, reported in three articles, provided similar results indicating no statistically significant differences in relapse rates between ECT and rTMS.61-63 A third trial in an MDD/bipolar mix population reported no statistically significant differences in response and remission rates during a 4-week observation following 3 weeks of acute treatment.60 However, results of this trial may be confounded by a large number of rTMS patients switching to ECT.

### Repetitive Transcranial Magnetic Stimulation Versus Sham

Two Tier 1 MDD-only studies found no statistically significant differences in relapse rates between rTMS and sham at 20 weeks69 and 6 months.77,99 A third Tier 1 study, involving an MDD/bipolar mix population, found no statistically significant differences in mean HAM-D scores during acute treatment at 3-month followup.82 These three studies provided insufficient evidence to draw a conclusion. Studies found that relapse rates do not differ significantly between rTMS and sham, however, too few patients were followed during the continuation phases of two of these studies and patients in the third received a co-intervention, providing insufficient evidence to allow for a conclusion.

Three Tier 2 studies provided data supporting the benefit for rTMS versus sham in maintaining remission. One MDD-only study found greater improvement in symptoms for rTMS patients than for the control patients at 2 weeks post-treatment.86 Only the high-frequency rTMS delivered to the left dorsolateral prefrontal cortex and the low-frequency rTMS delivered to the right left dorsolateral prefrontal cortex were more effective than the sham intervention. A second study, also in an MDD-only population, found a trend towards lower relapse rates for rTMS compared with sham, but statistically significant differences were not reported.87,115,116,119 One study involving an MDD/bipolar mix population reported that one patient who responded after rTMS maintained response at 2-month followup.88

One Tier 3 study, involving an MDD/bipolar mix population, showed benefit for rTMS versus sham for 3 weeks after treatment ended, but the benefit had disappeared at 3-month followup.90

### Cognitive Behavioral Therapy Versus Usual Care

No TRD (Tier 1) evidence was available for this comparison. One relatively large study (150 patients) reported in four articles involved a Tier 3, MDD-only population; it supported the benefit of CBT versus usual care in maintaining remission.95,96,120,121 The initial study compared 20 weeks of CBT with usual care (clinical management involving psychiatrist visits and antidepressant medications) and measured remission rates over a total of 68 weeks. Patients treated with CBT had a lower risk of relapse than sham-treated patients (hazard ratio 0.54; 95% CI, 0.32-0.93; P = 0.02). Followup of this population for 6 years after randomization showed small differences in recurrence rates for up to 3.5 years, although actuarial recurrence rates were only statistically significantly different through 20 weeks after randomization.

## Key Question 2 Efficacy or Effectiveness for Maintaining Remission or Treating Patients With Unresponsive or Recurrent Disease: Detailed Analysis

### Electroconvulsive Therapy Versus Repetitive Transcranial Magnetic Stimulation

#### Tier 1: Patients With two or More Treatment Failures

##### MDD-Only

No trial addressed maintenance of remission with ECT versus rTMS therapy in an MDD-only population.

##### MDD/Bipolar

No trial addressed maintenance of remission with ECT versus rTMS therapy in an MDD/bipolar mix population.

#### Tier 2: Patients With one or More Treatment Failures

##### MDD-Only

No trial addressed maintenance of remission with ECT versus rTMS therapy in an MDD-only population.

##### MDD/Bipolar

No trial addressed maintenance of remission with ECT versus rTMS therapy in an MDD/bipolar mix population.

#### Tier 3: Patients With Probable Treatment Resistance

##### MDD-Only

In the RCT of ECT versus rTMS,117,118 43 participants entered treatment, but only 41 continued in the 6-month followup to assess relapse rates (Table 35). In 20 participants, ECT was delivered according to a protocol with intensity 2.5 times the threshold energy and charge titrated up every second or third treatment to maintain a seizure length of 25 seconds or longer. Twenty-one participants received 20 sessions of high frequency at 90 percent motor threshold and 1,200 pulses per second. Prior to beginning treatment, the mean HAM-D_17_ scores (standard deviation) for patients were 28.4 (9.3) in the ECT group and 25.8 (6.1) in the rTMS group. At the beginning of followup (i.e., end of treatment), mean HAM-D_17_ scores were 7.9 (4.5) in the ECT group and 7.8 (3.7) in the rTMS group. These scores remained relatively stable at 3 and 6 months after treatment ended. At 3 months, 2 of 20 (10%) ECT-treated participants and 1 of 21 (5%) rTMS-treated participants relapsed. At 6 months, the figures were 4 of 20 (20%) and 4 of 21 (19%), respectively. Relapse rates were not statistically significantly different between these groups.

Table 35 Maintenance of remission of ECT versus rTMS: Tier 3, MDD

Author, year Design Quality | Intervention, Sample Size, and Study Details | Maintenance of Remission
Dannon et al., 2002;^117^ extension of Grunhaus et al., 2000^118^ RCT Fair | ECT plus antidepressant post-ECT (n = 20) 35% bilateral, mean sessions = 10.25 (3.1) rTMS plus antidepressant post-rTMS (n = 21) High frequency, 20 sessions Definitions Response: HAM-D_17_ reduction ≥ 50% and final GAS < 60 Relapse: return of depressive symptoms with HAM-D_17_ ≥ 16 Measured at end of treatment (response) and 3 and 6 months post-treatment (relapse) | HAM-D_17_ End of treatment (baseline), mean (SD) ECT: 7.9 (4.5) rTMS: 7.8 (3.7) P = NS 3-month post-treatment, mean (SD) ECT: 7.7 (5.0) rTMS: 6.4 (4.9) P = NS 6-month post-treatment, mean (SD) ECT: 8.4 (5.6) rTMS: 7.9 (7.1) P = NS 3-month relapse, number (%) ECT: 2 (10) rTMS: 1 (5) P = NS 6-month relapse, number (%) ECT: 4 (20) rTMS: 4 (19) P = NS

ECT = electroconvulsive therapy; GAS = Global Assessment Scale; HAM-D_17_ = Hamilton Rating Scale for Depression, 17-item instrument; n = number; NS = not significant; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation

##### MDD/Bipolar

Two additional RCTs compared ECT with rTMS in a mixed population of unipolar and bipolar depression. One RCT compared 6-month remission rates for ECT and rTMS in 46 patients referred for ECT to treat a major depressive episode (Table 36).61-63 Patients were not required to be treatment resistant, although on average patients had more than two previous treatment failures following adequate courses of medication—mean number (standard deviation) of failed treatments: ECT, 2.5 (1.4); rTMS, 2.4 (1). A small percentage of included participants had diagnoses of bipolar depression (9%) or psychosis (15%). Patients continued their usual medical care and psychotropic medications, with no changes in medication allowed during their active treatment. ECT was administered twice weekly. The number of ECT treatments was based on response, as determined by the referring physicians. High-frequency rTMS was administered for 15 consecutive weekday sessions. At the end of treatment, HAM-D_17_ scores were statistically significantly lower for the ECT group than for the rTMS group (P = 0.002), and the ECT group had a greater percentage of patients in remission (59.1% vs. 16.7%, respectively; P = 0.006). After 6 months of followup, HAM-D_17_ scores and remission rates were similar for the ECT and rTMS patients.

Table 36 Maintenance of remission of ECT versus rTMS: Tier 3, MDD and ≤ 20 percent bipolar disorder

Author, year Design Quality | Intervention and Sample Size Study Details | Maintenance of Remission
McLoughlin et al., 2007^61^ Eranti et al., 2007;^62^ Knapp et al., 2008^63^ RCT Fair | ECT (n = 22; n = 12 for 6-month followup) 82% bilateral, mean sessions 6.3 (SD: 2.5) rTMS (n = 24; n = 4 for 6-month followup) High frequency, 15 sessions Treatment strategy Augmentation Definitions Remission: HAM-D_17_ ≤ 8 Response: HAM-D_17_ reduction ≥ 50% Measured at end of treatment and 6 months after baseline (maintenance of remission) | HAM-D_17_ Baseline, mean (SD) ECT: 24.8 (5.0) rTMS: 23.9 (7.0) P = NS End of treatment, mean (SD) ECT: 10.7 (NR) rTMS: 18.5 (NR) P = 0.002 6-month (from baseline), mean (SD) ECT: 13.8 (NR) rTMS: 13.5 (NR) P = NS End of treatment remission, n (%) ECT: 13 (59.1) rTMS: 4 (16.7) P = 0.006 6-month remission, n (%) ECT: 6 (50) rTMS: 2 (50) P = NR
Hansen et al., 2010^60^ RCT Fair | ECT (n = 30) 100% unilateral, 9 sessions rTMS (n = 30) Low frequency, 15 sessions Treatment strategy Augmentation Definitions Response: HAM-D_17_ reduction ≥ 50% Remission: HAM-D_17_ < 12 Measured at end of treatment (week 3) and after 4 additional weeks (week 7) | HAM-D_17_ Baseline, median (range) ECT: 24 (16-34) rTMS: 24 (14-38) P = NS Week 3 remission rate (95% CI) ECT: 0.53 (0.34-0.72) rTMS: 0.27 (0.12-0.46) P = 0.035 Week 7 remission rate (95% CI) ECT: 0.57 (0.37-0.75) rTMS: 0.40 (0.23-0.59) P = 0.200

ECT = electroconvulsive therapy; HAM-D_17_ = Hamilton Rating Scale for Depression, 17-item instrument; n = number; NR = not reported; NS = not significant; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation

A second RCT reported 4 weeks of followup after 3 weeks of acute treatment with ECT (n=30) or rTMS (n=30). Patients were not specified to be treatment resistant, but were being referred for ECT for MDD. Most participants had unipolar depression, although 13 percent had bipolar depression. Patients continued their usual medications, with no changes in medication allowed during their active treatment. At the end of 3 weeks of acute treatment, ECT was significantly better than low-frequency rTMS (P = 0.035). At the end of 7 weeks (4 additional weeks), response and remission rates were not statistically significantly different for ECT compared with rTMS (P = 0.200). Response and remission rates continued to improve for the rTMS group, while no further reduction in HAM-D scores were observed in the ECT group (HAM-D score change from weeks 3–7; P = 0.001 and P = 0.78, respectively). However, these results are potentially confounded by increases in antidepressant dose and switching from rTMS to ECT during the followup period; 12 of 23 rTMS nonresponders switched to ECT during the 4-week followup.

### Repetitive Transcranial Magnetic Stimulation Versus Sham

#### Tier 1: Patients With two or More Treatment Failures

##### MDD-Only

No studies assessing maintenance of remission directly compared ECT, rTMS, VNS, and CBT in patients in this group. No sham-controlled studies addressed this population for ECT, VNS, or CBT. Two rTMS RCTs using a sham procedure as control addressed maintenance of remission (longer term relapse rates) in an MDD population (Table 37).69,77,99

Table 37 Maintenance of remission of rTMS versus sham: Tier 1, MDD

Author, year Design Quality | Intervention and Sample Size Study Details | Results on HAM-D Instruments
Avery et al., 2006^77,99^ RCT Fair | rTMS (n = 35, 11 for relapse followup) High frequency, 15 sessions over 4 weeks Sham (n = 33, 2 for relapse followup) Treatment strategy Mixed-within group differences 31% of rTMS group and 27% of control group continued taking medications Definitions Remission definition: HAM-D21 < 10 Response: HAM-D_17_ reduction ≥ 50% Remission: HAM-D_17_ < 8 Relapse: not defined Measured at end of treatment (visit 16) and reassessed 1 week later (visit 17); Response could enter 6-month followup | HAM-D_17_ 6-month relapse, n (%) rTMS: 6 (54.5); 1 lost to followup Sham: 1 (50); 1 lost to followup P = NR
Boutros et al., 2002^69^ RCT Fair | rTMS (n = 12, 6 for followup phase) High frequency, 10 sessions Sham (n = 9, 1 for followup phase) Treatment strategy Augmentation Definitions Response1 definition: >30% decrease in HAM-D_25_ Response2 definition: ≥50% decrease in HAM-D_25_**calculated from table Relapse: HAM-D_25_ ≥ baseline score ± 10% Relapse measured up until 20 weeks | HAM-D_25_ 20-week relapse, n (%) rTMS: 4 (66.6); 1 lost to followup Sham: 1/1 (100) P = NS

HAM-D = Hamilton Rating Scale for Depression, 17-item instrument or 25-item instrument; n = number; NR = not reported; NS = not significant; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation

Subjects in both rTMS trials were allowed to remain on psychotropic medications. The slightly larger and more recently conducted trial (n = 68)77,99 compared 15 sessions of high-frequency rTMS at 110 percent motor threshold with 1,600 pulses per session with a similarly delivered sham rTMS. At the end of treatment, responders could enter a 6-month followup to assess relapse. The smaller trial (n = 21)69 compared 10 sessions of high-frequency rTMS at 80 percent motor threshold with 800 pulses per session with a similarly delivered sham rTMS. At the end of treatment responders could enter a 20-week followup.

In both trials, significantly more rTMS-treated than sham-treated participants were classified as responders: respectively, 30.6 percent versus 6.1 percent (P = 0.008);77,99 and 50 percent versus 22 percent (P < 0.05)69. Of the small number of responders in these trials followed for maintenance of response, more than 50 percent relapsed; no statistically significant differences in relapse rates were observed between the rTMS and sham groups.

##### MDD/Bipolar

One trial addressed maintenance of remission with rTMS versus sham therapy in a mixed MDD-bipolar population (Table 38).82 Unlike other studies comparing rTMS and sham stimulation, in this study all patients also received a social support intervention. All patients had treatment failuresof at least two separate trials of a minimum of 4 weeks' duration at therapeutic dosages of antidepressant medications. Two of 48 enrolled patients had bipolar disease; both were randomized to the right rTMS group. Participants were randomized to left- or right-sided delivery of 10 sessions of rTMS or sham and followed for 3 months. At the end of active treatment as well as at 1- and 3-month followup, differences in mean HAM-D scores were not statistically significantly different for rTMS compared with sham. Statistically significant differences were noted between right and left rTMS and right and left sham, consistently showing better reductions for right-sided compared with left-sided delivery (P = 0.012). It is possible that the inclusion of a social support intervention may have muffled the effects of rTMS in this study.

Table 38 Maintenance of remission of rTMS versus sham: Tier 1, MDD and ≤ 20 percent bipolar disorder

Author, year Design Quality | Intervention and Sample Size Study Details | Results on HAM-D Instruments
Triggs et al., 2010^82^ RCT Fair | rTMS (n = 16 right(r); n = 18 left(l)) High frequency, 10 sessions over 2 weeks Sham (n = 14) Treatment strategy Augmentation Definitions Response: HAM-D_24_ reduction ≥ 50% Measured at end of treatment and 1 and 3 months after baseline (maintenance of response) | HAM-D_24_ End of treatment, mean (SD) rTMS(r): 13.7 (7.6) rTMS(l); 19.8 (9.1) Sham: 17.7 (10.4) P = 0.14 1 month, mean (SD) rTMS(r): 11.2 (7.5) rTMS(l); 18.2 (9.8) Sham: 19.7 (11.3) P = NS 3 months, mean (SD) rTMS(r): 11.7 (9.3) rTMS(l); 16.3 (11.5) Sham: 17.9 (11.6) P = NS

HAM-D24 = Hamilton Depression Scale, 24 item; n = number; NS = not significant; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation

#### Tier 2: Patients With one or More Treatment Failures

##### MDD-Only

No studies assessing maintenance of remission directly compared ECT, rTMS, VNS, and CBT. Two trials were relevant for this topic in this patient population (Table 39).

Table 39 Maintenance of remission of rTMS versus sham: Tier 2, MDD

Author, Year Design Quality | Intervention and Sample Size Study Details | Maintenance of Remission
Stern et al., 2007^86^ RCT Fair | High rTMS (n = 10) High frequency, 10 sessions Low-left rTMS (n = 10) Low frequency (1 Hz), Left-DLPFC, 10 sessions Low rTMS (n = 10) Low frequency, 10 sessions Sham (n = 15) Treatment strategy Switch Definitions Remission definition HAM-D_21_ ≤ 10 Response and remission measured at end of treatment (2 weeks) and after 1 and 2 weeks of followup | HAM-D_21_ End of treatment score, mean (SD) Left high rTMS: 15.1 (6) Left low rTMS: 27.6 (5.9) Low rTMS: 15.8 (4.8) Sham: 26.7 (3.6) P < 0.001 2-week followup score, mean (SD) Left high rTMS: 13.4 (5.6) Left low rTMS: 26.6 (3) Low rTMS: 14.9 (5.9) Sham: 26.8 (2.3) P < 0.001 End of treatment response, n (%) Left high rTMS: 5 (50) Left low rTMS: 0 (0) Low rTMS: 5 (50) Sham: 0 (0%) P = NR 2-week followup response, n (%) Left high rTMS: 4 (40) Left low rTMS: 0 (0) Low rTMS: 6 (60) Sham: 0 (0) P = NR End of treatment remission, n (%) Left high rTMS: 3 (33.3) Left low rTMS: 0 (0) Low rTMS: 1 (10) Sham: 0 (0) P = NR 2-week followup remission, n (%) Left high rTMS: 4 (40) Left low rTMS: 0 (0) Low rTMS: 3 (33.3) Sham: 0 (0) P = NR
O'Reardon et al., 2007,^87^ Janicak et al., 2007,^115^ Solvason et al., 2007^116^ Janicak et al., 2010 119 RCT Fair | rTMS (n = 99 for followup phase) High frequency, up to 30 sessions; rescue add-on permitted for symptom breakthrough (deterioration of CGI-S by 1 point over 2-week interval) during continuation Sham (n = 21 for followup phase) Treatment strategy Acute treatment switch; continuation rescue was augment to current pharmacotherapy Definitions Relapse defined as recurrence of the full syndrome of major depression per DSM-IV over ≥ 2 weeks: HAM-D_17_ ≥ 20; CGI-S ≥ 4 | HAM-D_17_ Remission Score at week 4, mean (SD) rTMS: -14.6 (6.16) Sham: -14.4 (6.11) Relapse Rates: Continuation at week 24, n (%) rTMS: 10 (10) Sham: 3 (13.6) P = NR

DLPFC = dorsolateral prefrontal cortex; HAM-D = Hamilton Rating Scale for Depression, 21-item instrument; Hz = hertz; MT = motor threshold; n = number; NR = not reported; NS = not significant; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation

Two RCTs compared rTMS with sham rTMS and assessed maintenance of remission following active treatment.86,87,115,116 One trial randomized 30 participants to 10 sessions of 3 different rTMS strategies (10 subjects in each group) and 15 participants to 10 sessions of similar sham strategies (5 subjects in each group). The three treatment groups were high frequency delivered to the left dorsolateral prefrontal cortex (left high), low frequency delivered to the left dorsolateral prefrontal cortex (left low), and low frequency delivered to the right left dorsolateral prefrontal cortex (right low). At the end of treatment, the left high and right low treatment groups had similar reductions in HAM-D_21_ scores, and these differences were statistically significantly greater than the left low and sham groups (P < 0.001). These differences remained after 2 weeks of followup; no left low- or sham-treated participants were in remission after 2 weeks, whereas 40 percent of left high- and 33 percent of right low-treated participants were in remission after 2 weeks (P = NR).

Another trial followed 120 patients over 24 weeks to assess the durability of acute response to high-frequency rTMS or sham.87,115,116,119 The acute phase of this trial was a switch strategy that randomized 155 severely depressed participants to active rTMS and 146 severely depressed participants to sham rTMS.87 After 6 weeks of acute treatment, 44 active rTMS-treated patients and 23 sham rTMS-treated patients were classified as responders. These patients entered a 3-week taper phase, and then began 24 weeks of open-label continuation followup.115 The remaining nonresponders were offered open-label rTMS, and an additional 32 participants from the original active rTMS group and 49 participants from the original sham rTMS group responded. Of these, durability of response was compared in 99 active rTMS responders and 21 sham responders. Open-label rTMS was permitted as rescue augmentation to the current antidepressant regimen for symptom breakthrough. Relapse was defined as recurrence of the full syndrome of major depression per DSM-IV criteria observed over at least 2 weeks. After 24 weeks, 10 (10%) active rTMS-treated participants relapsed and 3 (13.6%) sham-treated participants relapsed (P = NR).

##### MDD/Bipolar

One RCT compared rTMS with a sham procedure in 20 patients who had at least one adequate pharmacological failed trial during the current or previous episode (Table 40).88 The majority of included patients (80 percent) had two or more failed medication trials during the current episode. The inclusion criteria allowed patients to have comorbid psychiatric diagnoses provided that the onset occurred after the development of major depression and that the symptoms of major depression were more prominent. This resulted in the inclusion of one patient (assigned to sham) with a bipolar II, depressed diagnosis; the remainder had unipolar major depression. Patients assigned to active treatment (n = 10) received 10 sessions of high-frequency rTMS applied to the left dorsolateral prefrontal cortex. Patients assigned to the sham intervention (n = 10) received 10 sessions using the same device with the coil angled 30 to 45 degrees off the scalp and the bottom of the coil elevated 0.5 centimeters from the scalp. Response was defined by a 25-item HAM-D score ≤15 and a reduction in this score of 50 percent or more from baseline. At the end of treatment, one rTMS-treated patient (10%) and no sham-treated patients were categorized as responders (P = 0.09). The rTMS responder remained a responder during 2 months of followup.

Table 40 Maintenance of remission of rTMS versus sham: Tier 2, MDD and ≤ 20 percent bipolar disorder

Author, year Design Quality | Intervention and Sample Size Study Details | Maintenance of Remission
Berman et al., 2000^88^ RCT Fair | rTMS (n = 10; 1 for followup phase) High frequency, 10 sessions Sham (n = 10; 0 for followup phase) Treatment strategy Switch Definitions Response: HAM-D_25_ ≤ 15 and reduction from baseline ≥ 50% Response measured at end of treatment (2 weeks) and up to 2 months after treatment | HAM-D_25_ End of treatment score, mean (SD) rTMS: 24.6 (NR) Sham: 36.4 (NR) P < 0.01 End of treatment response, n (%) rTMS: 1 (10) Sham: 0 (0) P = 0.09 2-month maintained response, n (%) rTMS: 1 (100) Sham: 0 (100) P = NR

HAM-D = Hamilton Rating Scale for Depression, 25-item instrument; n = number; NR = not reported; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation

#### Tier 3: Patients With Probable Treatment Resistance

##### MDD-Only

No trial addressed maintenance of remission with rTMS versus sham therapy in an MDD-only population.

##### MDD/Bipolar

One RCT compared rTMS with a sham procedure in 19 patients with unspecified drug resistance (Table 41).90 The majority of patients had unipolar major depression, although 16 percent had bipolar depression. Patients assigned to active treatment (n = 12) received 5 sessions of high-frequency rTMS applied daily to the left prefrontal cortex for 5 days. Patients assigned to the sham intervention (n = 7) received five similar sessions with the coil placed perpendicular to the scalp surface without direct contact. Depression severity was measured by the 24-item HAM-D and the 21-item BDI. At the end of treatment, rTMS-treated patients had significantly lower HAM-D and BDI scores than sham-treated patients (P < 0.001). This statistically significant difference was maintained through week 4 (3 weeks after end of treatment), but patients reverted to the previous depressed mood at week 12 (P = NS).

Table 41 Maintenance of remission of rTMS versus sham: Tier 3, MDD and ≤ 20 percent bipolar disorder

Author, year Design Quality | Intervention, Sample Size, and Study Details | Maintenance of Remission
Bortolomasi et al., 2006 90 RCT Fair | rTMS (n = 12) High frequency, 5 sessions Sham (n = 7) Treatment strategy Augmentation Definitions Outcome = change in HAM-D_24_ and BDI_21_ | HAM-D_24_ Baseline score, mean (SD) rTMS: 25.17 (NR) Sham: NR (NR) P = NR End of treatment (at week 1), mean (SD) rTMS: 11.33 (NR) Sham: 18.29 (NR) P < 0.001 At week 4, mean (SD) rTMS: 11.42 (NR) Sham: 19.14 (NR) P < 0.001 At week 12, (NR) Both groups reverted to depressed mood P = NS BDI_21_ Results similar to HAM-D_24_

BDI_21_ = Beck Depression Inventory, 21-item instrument; HAM-D_24_ = Hamilton Rating Scale for Depression, 24-item instrument; n = number; NR = not reported; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation

### Cognitive Behavioral Therapy Versus Usual Care

#### Tier 1: Patients With two or More Treatment Failures

##### MDD-Only

No trial addressed maintenance of remission with CBT versus usual care in an MDD-only population.

##### MDD/Bipolar

No trial addressed maintenance of remission with CBT versus usual care in an MDD/bipolar mix population.

#### Tier 2: Patients With one or More Treatment Failures

##### MDD-Only

No trial addressed maintenance of remission with CBT versus usual care in an MDD-only population.

##### MDD/Bipolar

No trial addressed maintenance of remission with CBT versus usual care in an MDD/bipolar mix population.

#### Tier 3: Patients With Probable Treatment Resistance

##### MDD-Only

One trial, lasting 68 weeks and involving 158 participants, compared relapse rates for CBT and sham treatment (Table 42).95,96,120,121 All participants received usual clinical management and antidepressant drug continuation throughout the study. Participants also were followed for an additional 4.5 years.121 In the CBT group, 80 participants received 16 sessions over a 20-week period, plus two booster sessions approximately 6 to 14 weeks later. The sham group was seen by a psychiatrist every 4 weeks during the first 20 weeks and then every 8 weeks thereafter. The relapse outcome was defined by two criteria. The first criterion was meeting the criteria from the Diagnostic and Statistical Manual, Version 3, Revised for major depression for 1 month or more, with a HAM-D_17_ score of 17 or higher on two successive visits 1 week apart. The second criterion, which was applied only during the followup phase, was persistent symptoms for 2 months or more with a HAM-D_17_ score of 17 or higher at both visits. At the end of treatment (i.e., 20 weeks) and at 44 weeks, relapse rates were similar between CBT- and sham-treated participants. At the end of 68 weeks, significantly more sham-treated participants than CBT-treated participants had relapsed. Based on the combined definition of major depression with persistent symptoms, 29 percent of CBT-treated participants and 47 percent of sham-treated participants had relapsed by 68 weeks (hazard ratio for relapse 0.54; 95% CI, 0.32-0.93; P = 0.02). In a followup study of 135 participants over a total of 6 years, recurrence curves suggested the effects of CBT were persistent for up to 3.5 years, although actuarial recurrence rates were only statistically significantly different through 20 weeks after randomization.121

Table 42 Maintenance of remission of CBT versus usual care: Tier 3, MDD

Author, year Design Quality | Intervention, Sample Size, and Study Details | Maintenance of Remission
Paykel et al., 1999^95^ Scott et al., 2000;^96^ Scott et al., 2003^120^ Paykel et al., 2005 121 RCT Fair | CBT plus clinical management (n = 80) 16 session during 20 weeks Clinical management alone (n = 78) Treatment strategy Augmentation Definitions Relapse: HAM-D_17_ ≥ 17 on 2 successive visits 1 week apart, OR, at followup for ≥ 2 months | Relapse Rates, number (%) Major depression alone At 20 weeks CBT: 9 (11) Sham: 14 (18) P = NR At 44 weeks CBT: 15 (19) Sham: 25 (31) P = NR At 68 weeks CBT: 18 (22) Sham: 29 (36) P = 0.08 Hazard Ratio: 0.58 (95% CI, 0.37-1.07) Relapse Rates, number (%) Major depression plus symptoms At 20 weeks CBT: 8 (10) Sham: 14 (18) P = NR At 44 weeks CBT: 19 (24) Sham: 31 (40) P = NR At 68 weeks CBT: 23 (29) Sham: 37 (47) P = 0.02 Hazard Ratio: 0.54 (95% CI, 0.32-0.93) Recurrence rate in long-term followup At 120 weeks CBT: 27(38) Sham: 28(43) P = 0.25 At 275 weeks CBT: 42(60) Sham: 42(65) P = 0.33

CBT = cognitive behavioral therapy; CI = confidence interval; HAM-D_17_ = Hamilton Rating Scale for Depression, 17-item instrument

##### MDD/Bipolar

No trial addressed maintenance of remission with CBT versus usual care in an MDD/bipolar mix population.

## Key Question 3 Efficacy or Effectiveness for Treating Treatment-Resistant Depression for Particular Symptom Subtypes

### Overview

This KQ focused on the comparative benefit of treatment for patients with TRD and an accompanying symptom subtype. Specifically of interest were symptom groups such as psychosis, catatonia, or melancholy, subtypes that can accompany depression and which are often used to inform clinical interventions. We identified no studies that address this question in TRD (Tier 1) patients. However, a consideration of evidence from all tiers identified one relevant Tier 3 trial, reported in two articles.118,122 The study was a head-to-head comparison of ECT and rTMS in psychotic and nonpsychotic patients with TRD. Though the study was rated poor, we include it here because it provides some evidence on the efficacy of rTMS in patients with TRD and psychosis.

### Strength of Evidence: Tier 1 (TRD)

We identified no eligible Tier 1 studies.

### Key Points

The one study available on this topic118,122was rated poor quality and involved a Tier 3 population with a primary finding that ECT produced significantly better outcomes than rTMS. A secondary analysis indicated that the presence of psychotic symptoms may have influenced the effect of these two interventions: psychotic patients appeared to have better outcomes with ECT than with rTMS. In nonpsychotic patients, the effect of the two interventions was similar. Of note, however, the differential use of psychotropic medications during the course of the trial may have biased the results in favor of ECT. The two groups were being treated with different drugs at baseline; ECT patients were allowed to continue any medication, including antipsychotics, at a stable rate, but the rTMS patients were limited to clonazepam.

### Detailed Analysis

#### ECT Versus rTMS

There were no eligible studies in Tier 1 or 2. In Tier 3, there were no eligible studies in an MDD-only population and one study (three articles) in an MDD/bipolar mix population.

#### Tier 1

There were no eligible studies.

#### Tier 2

There were no eligible studies.

#### Tier 3

There were no eligible studies in an MDD-only population and one study (two articles) in an MDD/bipolar mix population.

##### MDD-Only

There were no eligible studies.

##### MDD/Bipolar Mix

The study was undertaken with 40 inpatients and outpatients who had been referred for ECT; detailed information is available in the evidence table in Appendix D. The investigators randomized patients to either ECT or rTMS. Of those receiving ECT, 10 had TRD only and 10 had TRD and psychosis; of those receiving rTMS, 11 had TRD only and 9 had TRD and psychosis. The primary comparison was the change in HAM-D score at 2 weeks and end of treatment (approximately 4 weeks), with higher scores better than lower scores.

Overall, patients responded better to ECT than to rTMS (P < 0.05). With regard to psychotic versus nonpsychotic patients, the study reported two important findings. First, in nonpsychotic patients, ECT and rTMS were equally effective. HAM-D_17_ scores at the end of treatment for ECT and rTMS were 13.9 and 11.0 (P = NS), respectively. Second, in psychotic patients, ECT appeared to be more effective than rTMS; HAM-D_17_ scores at the end of treatment were 8.4 and 20.8 (P = 0.01), respectively.

This study has limitations for our KQ because treatment bias restricted applicability to our population of interest. The ECT group had been allowed to continue on any psychotropic medication, including antipsychotic medications, at a stable dose, while the rTMS group had all their psychotropic medications discontinued although they were prescribed clonazepam (a benzodiazepine derivative with anticonvulsant, muscle relaxant, and anxiolytic properties) to reduce anxiety, limit insomnia, and help prevent seizures. This variation introduced a treatment, or co-intervention, bias. In this sample, 25 patients had been treated unsuccessfully 2 or more times and 15 patients either had been treated unsuccessfully only one time or had had no treatment failures; nonetheless, all had been referred for ECT, and so we classified them as Tier 3 (probable treatment resistance).

## Key Question 4 Organization of Safety, Adverse Events, and Adherence

KQ 4 contains information addressing safety, adverse events, and adherence in the use of nonpharmacological treatments to treat TRD. The following section is split into four segments, each comparing the effects of the four nonpharmacologic interventions (ECT, rTMS, VNS, CBT/IPT) with each other (head-to-head comparisons) or with control interventions (e.g., sham procedures) but focusing on a different outcome. KQ 4a addresses the impact on cognitive functioning. KQ 4b examines specific adverse events (other than cognitive functioning) that were assessed systematically. The next two segments use two measures of study withdrawals. KQ 4c examines general tolerability to the treatments by using withdrawals specifically due to adverse events. The final segment, KQ 4d, examines adherence by examining withdrawals for any reason (overall withdrawals), as only a few studies measured adherence as an outcome.

## Key Question 4a Cognitive Functioning—Overview

This KQ concerns the issue of whether the four nonpharmacologic interventions (ECT, rTMS, VNS, CBT/IPT) compared with each other (head-to-head comparisons) or against control interventions (e.g., sham procedures) have different effects on cognitive functioning. Cognitive functioning is measured in several domains, such as the Mini-Mental Status Examination (MMSE) and various intelligence, learning, or memory tests such as the Rey Auditory Verbal Learning Test (RAVLT), the Wechsler Adult Intelligence Scale (WAIS), and the Cambridge Examination for Mental Disorders of the Elderly (and the cognitive, self-contained part of the Cambridge instrument denoted CAMCOG). Appendix F lists the major instruments used to detect or diagnose cognitive impairments across a wide range of faculties.

We included 11 studies of either good or fair quality; of these, 5 compared ECT to rTMS, 5 evaluated rTMS against a sham procedure, and one compared ECT to ECT plus rTMS (Table 43). Only one had cognitive functioning as a primary outcome of interest. All tested cognitive functioning effects in the acute phase of treatment and did not address long-term or cumulative effects of the interventions. In the detailed analysis section below, we consider first the studies involving only patients with MDD and then the mixed MDD/bipolar populations. For studies that did not report sufficient information to determine if the population was MDD-only or a mixed MDD/bipolar population, we placed them in the mixed MDD/bipolar section. Information is presented for the three tiers used throughout this report: Tier 1, two or more treatment failures; Tier 2, one or more treatment failures; and Tier 3, “probable” treatment resistance.

Table 43 Number of good- and fair-quality studies by TRD tier and diagnostic mix for KQ 4a

Comparison | Tier | MDD-Only | MDD and Bipolar Disorder
ECT vs. rTMS | Tier 1: ≥ 2 treatment failures | 2 | 0
ECT vs. rTMS | Tier 2: ≥ 1 treatment failure | 1 | 0
ECT vs. rTMS | Tier 3: Probable | 0 | 2 additional
ECT vs. ECT + rTMS | Tier 1: ≥ 2 treatment failures | 1 | 0
rTMS vs. sham | Tier 1: ≥ 2 treatment failures | 3 | 0
rTMS vs. sham | Tier 2: ≥ 1 treatment failure | 2 additional | 0

ECT = electroconvulsive therapy; MDD = major depressive disorder; rTMS = repetitive transcranial magnetic stimulation, vs. = versus

When considering only studies conducted in Tier 1 patients with MDD, there were two head-to-head trials of ECT versus rTMS,58,123 one trial comparing ECT to ECT plus rTMS,64 and three rTMS versus sham studies (four articles).73,76,77,99

Additional eligible studies were found in Tiers 2 and 3. One head to head study was conducted in Tier 2 patients and compared ECT to rTMS.59 Two studies (six articles) comparing rTMS to sham were conducted in Tier 2 patients with MDD.84,85,87,115,116,119,124,125 Two head-to-head studies (four articles) in Tier 3 compared ECT with rTMS.61-63,126

### Strength of Evidence: Tier 1 (TRD)

Table 44 shows the evidence for studies limited to Tier 1, patients that have two or more previous treatment failures for depression. The two studies that compare ECT versus rTMS, one an RCT and the other a cohort study, provide insufficient evidence to determine whether there is a difference in cognitive outcomes between ECT and rTMS during the acute phase of treatment. In the three studies that populate Tier 1 on comparisons of rTMS versus sham, there is insufficient evidence to assess the impact of rTMS on cognitive functioning during acute phase treatment.

Table 44 Strength of Evidence: impact on cognitive functioning – Tier 1

Comparison | Number of Studies; Subjects | Risk of Bias Design Quality | Consistency | Directness | Precision | Results Strength of Evidence
ECT vs. rTMS | 2; 72 | Medium 1 RCT, and 1 prospective cohort study Both fair | Inconsistent | Direct | Imprecise | Some evidence suggests no difference between treatments, whereas some evidence suggests that ECT has a deleterious impact on cognitive functioning compared to rTMS Insufficient
ECT vs. ECT plus rTMS | 1;22 | High 1 RCT Fair | Unknown | Indirect | Imprecise | Insufficient
rTMS vs. sham | 3; 101 | Medium 3 RCTs, 1 good, 2 fair | Inconsistent | Indirect | Imprecise | Some evidence suggests no difference between rTMS and sham, whereas some evidence suggests that rTMS improves cognitive functioning compared to sham Insufficient

ECT = electroconvulsive therapy; RCT(s) = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; vs. = versus

## Key Question 4a Cognitive Functioning—Key Points

Limited evidence addressed the impact of these procedures on cognitive functioning; no evidence was available for VNS or CBT/IPT.

Overall, we included 11 studies (20 articles) that examined cognitive functioning during acute phase treatment.58,59,61-64,73,76,77,84,85,87,99,115,116,119,123-126 Nine studies were limited to patients with MDD-only, 4 comparing ECT with rTMS,58,59,123,126 and 5 studies (12 articles) comparing rTMS with sham.73,76,77,84,85,87,99,115,116,119,124,125 Two studies (five articles) included a mixed (20 percent or less bipolar) population; one study (three articles) compared ECT with rTMS,61-63 and the second study compared ECT versus ECT plus rTMS.64

Included studies are mostly small; samples had a mean of 35 participants per study and ranged from 15^76^ to 68^77,99^ participants per study with the exception of one study that had 325 participants.87,115,116,119,124,125 Overall, cognitive functioning impacts did not differ much between treatment groups. Some tests did show a statistically significant difference but not necessarily a clinically meaningful one.73,76,77,84,85,99

Any negative cognitive functioning impact that did occur with ECT faded away relatively quickly. Differences tended to dissipate to insignificance between end of treatment assessments and subsequent assessments (mean 8.8 days,126 2 weeks,126 and 6 months61-63).

## Key Question 4a Cognitive Functioning—Detailed Analysis

### Electroconvulsive Therapy Versus Repetitive Magnetic Stimulation

There were two studies, an RCT and a prospective cohort study, in Tier 1. There was one study in Tier 2. In Tier 3, there was one RCT and one prospective cohort study.

#### Tier 1

There were two studies, an RCT and a prospective cohort study.

##### MDD-Only

Two studies, shown in Table 45, provided data on the head-to-head comparison of ECT versus rTMS.58,123 One was an RCT that compared right unilateral ECT for 2 weeks in 20 patients with high-frequency rTMS in 22 patients.58 At the end of treatment at 2 weeks and after a 2-week followup, for a total of 4 weeks, the groups did not differ on cognitive tests that included the Weschler Adult Intelligence Scale, Weschler Memory Scale, and the Rivermead Behavioral Memory Test.

Table 45 Impact on cognitive functioning of ECT versus rTMS: Tier 1, MDD

Author, Year Design Endpoint Quality | Intervention and Sample Size Study Details | Outcomes
Rosa et al, 2006^58^ RCT Primary endpoint was after up to 4 weeks of active treatment Fair | ECT (n = 20) % bilateral NR, mean sessions 10 (SD 1.5) rTMS (n = 22) High frequency, 10-20 sessions (2-4 weeks) | WAIS-R, subsections of WMS (digit span) and RBMT;: ECT vs. rTMS: no significant differences
Schulze-Rauschenbach et al., 2005^123^ Prospective cohort Outcomes measured 8.8 days on average after last treatment Fair | ECT (n = 14) Right unilateral txt for 2 weeks rTMS (n = 16) High frequency, mean 10.8 sessions (SD 1.4) | Learning and Anterograde Memory with AVLT: Recall after interference: Before treatment ECT: 2.8 (2.2) vs. rTMS: 3.2 (1.9) 1 week after treatment ECT: 3.9 (1.9) vs. rTMS: 1.8 (2.0), P < 0.01 Recall after delay: Before treatment ECT: 2.4 (1.8) vs. rTMS: 3.2 (1.6) 1 week after treatment ECT: 4.2 (1.6) vs. rTMS: 2.4 (2.0), P < 0.05 Other AVLT subscales or the Memory for Persons Test (MPT): No significant differences Retrograde memory with AVLT Recall: No difference on recall or recognition hits Recognition false alarms 1 week after treatment: ECT: 5.0 (3.0) vs. rTMS: 1.1 (1.1), P < 0.05 Four-card task - Free recall: 1 week after treatment ECT: 0.4 (0.5) vs. rTMS: 1.4 (1.2), P < 0.05 Subjective memory with SSMQ: Before treatment ECT: -20.7 (19.0) vs. rTMS: -16.8 (16.9) 1 week after treatment ECT: -15.2 (25.2) vs. rTMS: 3.8 (11.8), P < 0.05

AVLT = Auditory Verbal Learning Test; ECT = electroconvulsive therapy; MPT = memory persons test; n = number; NR = not reported; pt = patient; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; SSMQ = Squire Subjective Memory Questionnaire; txt = treatment; vs. = versus; WAIS-R = Weschler Adult Intelligence Scale-Revised; WMS = Weschler Memory Scale

The other was a prospective cohort study of 30 subjects.123 The study used RAVLT, Memory for Persons Test, Autobiographical Memory Interview, Four card task, and the Squire Subjective Memory Questionnaire (SSMQ) to test cognitive functioning. Several of the cognitive tests showed a statistically significant difference between the ECT and rTMS groups, with ECT having a deleterious effect on cognitive functioning compared to rTMS. Two sections of the RAVLT showed significant differences in post-treatment measures in favor of rTMS: recall after interference (ECT 3.9 vs. rTMS 1.8; P < 0.01), recall after delay (ECT 4.2 vs. rTMS 2.4; P < 0.05). Differences were also found in retrograde memory function. The ECT group made significantly more errors than those in the rTMS group in recognizing words learned before treatment (ECT 5.0 vs. rTMS 1.1, P = 0.025). After treatment, ECT recipients also recalled significantly fewer items (0.4) from the visual card task administered before treatment than did the rTMS group (1.4, P = 0.012). Subjective memory, measured using the SSMQ, improved in the rTMS group from -16.8 to 3.8 and stayed similar in the ECT subjects, changing from -20.7 to -15.2 at endpoint (P < 0.05 for rTMS vs. ECT).

##### MDD/Bipolar mix

There were no eligible studies.

#### Tier 2

One fair rated RCT comparing rTMS to ECT in 40 MDD only patients is presented in Table 46.^59^ There were no differences in cognitive functioning as measured by the MMSE.

Table 46 Impact on cognitive functioning of ECT versus rTMS: Tier 2, MDD

Author, Year Design Endpoint Quality | Intervention and Sample Size Study Details | Outcomes
Grunhaus et al., 2003^59^ RCT 2-4 weeks Fair | ECT (n = 20) 35% bilateral, mean sessions 10.25 (SD 3.1) rTMS (n = 20) High frequency, 20 sessions (4 weeks) | MMSE Baseline (SD) ECT: 25.8 (3.4) rTMS: 27.8 (3.0) Week 2 (SD) ECT: 26.3 (2.9) rTMS: 27.8 (3.0) End of treatment (SD) ECT: 27.1 (2.5) rTMS: 28.0 (1.8) Group by time interaction, P = NS

ECT = electroconvulsive therapy; NS = not significant; P = p-value; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation; vs. = versus

#### Tier 3

There were no MDD studies and in an MDD/bipolar mix there was one RCT and one prospective cohort study (Table 47).

Table 47 Impact on cognitive functioning of ECT versus rTMS: Tier 3, MDD and ≤ 20 percent bipolar disorder

Author, Year Design Quality | Intervention and Sample Size Study Details | Outcomes
McLoughlin et al., 2007^61^ Eranti et al., 2007^62^ and Knapp et al., 2008^63^ RCT Primary endpoint is end of treatment (at clinicians' discretion for ECT group, 3 weeks in rTMS) Good | ECT (n = 24) 82% bilateral rTMS (n = 22) High frequency, 15 sessions | CAMCOG attention and orientation subscale (max = 17), n (SD). Baseline ECT: 12.8 (3.2) rTMS: 14.7 (3.0) End of treatment ECT: 13.9 (3.6) rTMS: 13.5 (3.3) 6 mos ECT: 13.9 (3.5) rTMS: 13.4 (3.8) P = 0.004 CAMCOG subscales (verbal fluency, anterograde memory, and retrograde memory): No significant differences MMSE Baseline, n ECT: 16 rTMS: 22 Baseline, mean (SD) ECT: 24.3(3.6) rTMS: 25.7 (3.9) End of treatment/6-month followup, mean (SD) ECT: 25.6 (3.9)/25.4 (5.3) rTMS: 24.4 (5.3)/24.7 (4.8) Change at end of treatment, mean: ECT: 1.3 rTMS: -1.3 P < 0.08 Columbia ECT Subjective Side Effects Schedule for self-reported cognitive side effects: No significant differences on the self-reported cognitive side effects.
O'Connor et al., 2003^126^ Prospective cohort Outcomes recorded at end of treatment and after 2 weeks of followup Fair | ECT (n = 14) unilateral, 3 times per week for 2 to 3 weeks rTMS (n = 14) high frequency, 10 sessions | RAVLT, Acquisition, mean (SD). Baseline ECT 43.78 (11.07) rTMS 43.71 (12.09). End of treatment ECT 29.14 (7.93) rTMS 43.00 (10.09) P < 0.01 2 weeks later: ECT 46.92 (10.80) rTMS 44.07 (10.43) P > 0.05. RAVLT, Retention (15-item word list after a 20-minute delay interval), mean (SD) Baseline: ECT 8.07 (4.49) rTMS 9.76 (3.08) End of treatment: ECT 2.14 (1.99) rTMS 8.23 (2.80) 2 weeks later ECT 8.92 (4.14) rTMS 8.31 (4.07). TNET Baseline: ECT 64.30 (19.40) rTMS 55.63 (18.12). End of treatment: ECT 39.10 (13.21) rTMS 57.81(18.33) 2 weeks later: ECT 59.20 (20.67) rTMS 61.54 (19.12).

CAMCOG = Cambridge Examination for Mental Disorders in the Elderly; ECT = electroconvulsive therapy; MMSE = mini-mental state examination; mos = months; MT = motor threshold; n = number; NR = not reported; pps = pulses per second; RAVLT = Rey Auditory Verbal Learning Test; RCT = randomized controlled trial; Rtms = repetitive transcranial magnetic stimulation

##### MDD-Only

There were no eligible studies.

##### MDD/Bipolar mix

One RCT and one prospective cohort study provide head-to-head evidence comparing rTMS with ECT for mixed MDD/bipolar populations, as shown in Table 47.^61-63,126^ The RCT compared high-frequency rTMS (n = 22, for 15 sessions) versus ECT (n = 24, mean number of sessions 6.3, range 2-10, based on physicians' opinion).61-63 The primary cognitive tests included the MMSE and CAMCOG. There were no statistically significant differences in MMSE scores or total CAMCOG scores between the ECT group and the rTMS group. In addition, most of the CAMCOG subscales (verbal fluency, anterograde memory, and retrograde memory) showed no significant differences; but subjects treated with ECT did statistically significantly better than those treated with rTMS on the attention and orientation subscale (respectively, an increase of 1.1 from baseline versus a decline of 1.2 from baseline; P = 0.004).

### Electroconvulsive Therapy Versus Electroconvulsive Therapy Plus Repetitive Transcranial Magnetic Stimulation

Within Tier 1, there was one RCT identified in an MDD patient population.

#### Tier 1

One RCT was conducted in 22 MDD patients (Table 48).64 Memory problems, as measured by a single self-report question, were reported by twice as many patients in the ECT only group (P = NS).

Table 48 Impact on cognitive functioning of ECT versus ECT plus rTMS: Tier 1, MDD

Author, Year Design Endpoint Quality | Intervention and Sample Size Study Details | Outcomes
Pridmore et al., 2000^64^ RCT Outcomes measured after 2 weeks Fair | ECT (n = 11) 100% unilateral, 6 sessions ECT plus rTMS (n = 11) ECT: 100% unilateral (day 1), plus high frequency rTMS: (days 2-5) Repeated in week 2, 8 sessions | Memory complaints, n ECT: 9 ECT plus rTMS:.4 P = NS

ECT = electroconvulsive therapy; NS = not significant; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; vs. = versus

### rTMS Versus Sham

Within Tier 1, three RCTs were identified in an MDD patient population, and no eligible studies in an MDD/bipolar mix population were identified. Two additional RCTs in an MDD patient population was identified when accounting for a Tier 2 definition. For MDD/bipolar patients, there were no eligible studies in Tier 2. Within Tier 3 in an MDD-only population, there were no eligible studies.

#### Tier 1

There were three RCTs in MDD patients and one RCT in patients with MDD/bipolar mix (Table 49).

Table 49 Impact on cognitive functioning of rTMS versus sham: Tier 1, MDD

Author, Year Design Endpoint Quality | Intervention and Sample Size Study Details | Outcomes
Avery et al., 2006^77,99^ RCT Outcomes measured after 2 weeks (except GOAT) Good | rTMS (n = 35) High frequency, 15 sessions over 4 weeks Sham (n = 33) | RAVLT, Digit Symbol Test and Digit Span (from the WAIS-R), Trail Making Test Parts A and B, MMSE, COWAT, the color Stroop Test: or GOAT, 5 minutes after each rTMS session: No significant differences -
Holtzheimer et al., 2004^76^ RCT Outcomes measured after 2 weeks Fair | rTMS (n = 7) High frequency, 10 sessions Sham (n = 8) | Verbal Memory RAVLT, Trial 7, mean score (%): rTMS: 12.7 (2.1) Sham: 12.0 (2.3), P < 0.05. Neuropsychological measures of attention, verbal memory, psychomotor speed, and mental flexibility. Outcome measures: RAVLT subscales, Digit Symbol Test, Digit Span, and the Stroop Test: No significant differences
Padberg et al., 1999^73^ RCT Outcomes measured after 1 week Fair | rTMS (n = 6) High frequency, 5 sessions Low-left rTMS (n = 6) 0.3 Hz, Left-DLPFC, 5 sessions Sham (n = 6) | Verbal memory performance Data NR Group by time interaction P = 0.006

COWAT = Controlled Oral Word Association Test; GOAT = Galveston Orientation and Amnesia Test; MMSE = mini-mental state examination; n = number; RAVLT = Rey Auditory Verbal Learning Test; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; WAIS-R = Weschler Adult Intelligence Scale-Revised

##### MDD-Only

Three Tier 1 RCTs as shown in Table 49 evaluated rTMS against sham. The largest (n = 68) used high-frequency rTMS for 15 sessions and took cognitive measurements at baseline and following the final treatment. None of the tests showed a statistically significant difference between the two groups.77,99 The other two studies were smaller. One (n = 15) used high-frequency rTMS for ten sessions.76 Tests included the RAVLT, Digit Symbol Test, Digit Span, and Stroop Test. Subjects in the two groups performed equally well with the exception of one measure of verbal memory, Trial 7 of RAVLT, in which subjects who received rTMS performed slightly better (12.7) than sham subjects (12.0, P < 0.05). Subjects treated with rTMS had mean neuropsychological tests that were either improved or equal to baseline levels of functioning. The other (n = 18) randomized subjects to five sessions of high-frequency rTMS, low frequency rTMS, or sham.73 Between-group differences in changes in verbal memory performance were identified (Date NR, group by time interaction P = 0.006). The high-rTMS group showed improvement, the sham group showed deterioration, and the sham group showed no change in learning performance.

##### MDD/Bipolar mix

No eligible studies identified.

#### Tier 2

There were two RCTs in MDD patient populations. Within an MDD/bipolar population there were no eligible studies (Table 50).

Table 50 Impact on cognitive functioning for rTMS versus sham: Tier 2, MDD

Author, Year Design Endpoint Quality | Intervention and Sample Size Study Details | Outcomes
O'Reardon et al., 2007;^87^ Janicak, 2007;^115^ Sovason et al., 2007;^116^ Janicak et al., 2010^119^ Demitrack et al., 2009;^124^ Janicak et al., 2008^125^ RCT Outcomes measured at 6 weeks Good | rTMS (n = 165) High frequency,, 20-30 sessions Sham (n = 160) | MMSE Baseline (SD) rTMS: 28.5 (1.5) Sham: 28.4 (1.7) At 6 weeks- end of acute treatment (SD) rTMS: 28.8 (1.4) Sham: 28.4 (1.8) P = NS Short-term recall – BSRT Baseline (SD) rTMS: 47.6 (12.3) Sham: 47.4 (13.3) At 6 weeks- end of acute treatment (SD) rTMS: 49.4 (12.3) Sham: 49.1 (12.9) P = NS Amnesia Scores (AMI – Short Form) At 6 weeks – end of acute treatment (SD) rTMS: 88.5 (8.7) Sham: 89.8 (8.1) P = NS
Manes et al., 2001^84^ and Moser et al., 2002^85^ RCT Outcomes measured a mean of 3 days following 1 week treatment Fair | rTMS (n = 10) High Frequency 5 sessions Sham (n = 10) | MMSE, Trail Making Test A, The Stroop Test, WAIS-R Digit Symbol; COWAT, Boston Naming Test, Sentence Repetition, RAVLT (% of learned words recalled after delay), Judgment of Line Orientation: No significant differences Trail Making Test B, seconds Baseline rTMS: 87.22 Sham: 103.67 Mean of 3 days after end of treatment rTMS: 58.59 Sham: 100.64 P < 0.05

AMI = Autobiographical Memory Interview; COWA = Controlled Oral Word Association; MMSE = mini-mental state examination; RAVLT = Rey Auditory Verbal Learning Test; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; WAIS-R = Wechsler Adult Intelligence Scale-Revised

##### MDD-Only

One RCT (n = 20) (two articles) compared high-frequency rTMS intervals, for five sessions, with a sham procedure (see Table 50).84,85 Cognitive testing was completed at baseline and 3 days after the last (fifth) treatment. The rTMS group showed a significant improvement in Trail Making Test B test scores (baseline score: 87.22; endpoint: 58.59; P < 0.05), whereas scores for the sham group did not significantly change. The groups did not differ significantly on any other cognitive tests conducted (MMSE, Trail Making Test A, The Stroop Test, WAIS-R Digit Symbol; Controlled Oral Word Association Test, Boston Naming Test, Sentence Repetition, RAVLT, or Judgment of Line Orientation).

The second RCT (n = 325) compared high-frequency rTMS intervals, at 6 weeks, with a sham procedure (see Table 50).87,115,116,119,124,125 Cognitive testing was completed at baseline and at 6 weeks. The groups did not differ significantly on any of the cognitive tests conducted, which included the MMSE, the Buschke Selective Reminding Test, and the Autobiographical Memory Interview, nor were there significant changes within the groups from baseline to endpoint at 6 weeks.

##### MDD/Bipolar mix

There were no eligible studies.

#### Tier 3

In MDD-only and MDD/bipolar populations there were no eligible studies.

## Key Question 4b Specific Adverse Events—Overview

This part of KQ 4 concerns specific adverse events from one of the procedural interventions recorded using a systematic method. Results are presented for good- or fair-quality studies.

Overall, 8 studies (16 articles) presented in Table 51^61-64,77,83,87-89,98,99,115,116,119,124,125^ assessed adverse events during acute phase treatment using a systematic method of which only 3 studies (4 articles) found any significant differences in adverse events.77,88,89,99

Table 51 Number of good- and fair-quality studies by TRD tier and diagnostic mix that measure adverse events systematically for KQ 4b

Comparison | Tier | MDD-Only | MDD and Bipolar Disorder
ECT vs. rTMS | Tier 3: Probable | 0 | 1 additional
ECT vs. ECT+rTMS | Tier 1: ≥ 2 treatment failures | 1 | 0
rTMS vs. sham | Tier 1: ≥ 2 treatment failures | 1 | 0
rTMS vs. sham | Tier 2: ≥ 1 treatment failure | 2 additional | 2 additional
VNS vs. sham | Tier 1: ≥ 2 treatment failures | 0 | 1

ECT = electroconvulsive therapy; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation

### Strength of Evidence: Tier 1 (TRD)

Table 52 documents the strength of evidence concerning specific adverse events in both disease categories combined, limited to Tier 1 studies. It included three comparisons, one of ECT versus ECT plus rTMS,64 another study (two articles) that compares rTMS to sham77,99 and one that compares VNS to sham.98 The comparison of ECT with ECT plus rTMS found no differences. These studies provide low strength of evidence that both rTMS and VNS compared to sham lead to a greater incidence of adverse events. This low strength of evidence is subject to change with the addition of more studies.

Table 52 Strength of Evidence: specific adverse events – Tier 1

Comparison | Number of Studies; Subjects | Risk of Bias Design Quality | Consistency | Directness | Precision | Results and Strength of Evidence
ECT vs. ECT plus rTMS | 1; 22 | High 1 RCT Fair | Unknown, single study | Indirect | Imprecise | No significant differences in specific adverse events Low
rTMS vs. sham | 1; 68 | High 1 RCT Good | Unknown, single study (as most of the specific adverse events were assessed by a single study) | Indirect | Imprecise | Some evidence suggests no significant differences in specific adverse events, while some evidence suggests that rTMS results in more scalp pain at the stimulation site Low
VNS vs. sham | 1; 235 | Medium 1 RCT Fair | Unknown, single study | Indirect | Imprecise | Some differences in specific adverse events reported but P = NR Low

CBT = cognitive behavioral; ECT = electroconvulsive therapy; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation, VSN = vagus nerve stimulation

One RCT comparing VNS with sham provided low strength of evidence that there were no significant differences overall in the systematic assessment of specific adverse events, although the reporting of particular events appears to be numerically higher in the VNS group.

## Key Question 4b Specific Adverse Events—Key Points

Evidence on adverse events is very limited; only 8 studies (16 articles)61-64,77,83,87-89,98,99,115,116,119,124,125 reported specific adverse events using a systematic method; 4 of these found some differences in adverse events.77,88,89,98,99 This section does not include studies assessing cognitive function; those are addressed in KQ 4a. The single good-quality RCT, a head-to-head comparison of ECT versus rTMS, did not report any significant differences in specific adverse events.61-63 Five of the studies compared rTMS versus sham procedures; of these, one used escitalopram (20 mg) in both groups. These five studies provide some evidence that rTMS results in more scalp pain and discomfort at the stimulation site, toothache, and muscle twitching than sham, but that there is no difference in headaches or seizures and the adverse effects tend to fade rapidly.

One RCT comparing VNS with sham did not test the statistical significance of differences in specific adverse events. This study did report an increased frequency of particular events with VNS treatment—including voice alteration, cough, dyspnea, dysphasia, and neck pain.

## Key Question 4b Specific Adverse Events—Detailed Analysis

### Electroconvulsive Therapy Versus Repetitive Transcranial Magnetic Stimulation

There were no eligible studies in Tier 1 or 2. In Tier 3 there were no eligible studies in an MDD-only population and one study (three articles) in an MDD/bipolar mix population.

#### Tier 1

There were no eligible studies.

#### Tier 2

There were no eligible studies.

#### Tier 3

There were no eligible studies in an MDD-only population and one study (three articles) in an MDD/bipolar mix population.

##### MDD-Only

There were no eligible studies.

##### MDD/Bipolar mix

Table 53 shows one head-to-head RCT that compared ECT (n = 24) with rTMS (n = 22) and did not report any significant differences in specific adverse events.61-63 The study used the Columbia ECT Subjective Side Effects Schedule, modified to include potential rTMS side effects (e.g., seizure induction, scalp discomfort, hearing loss) and any upredictable side effects. The study reported that the ECT group had lower overall scores for subjective side effect symptoms at the end of treatment (P = 0.02), but did not find differences in the group by time interaction analysis (P = 0.49). The study did not report frequency of each specific side effects. Additionally there was one death in the rTMS arm; however, it was unrelated to treatment.

Table 53 Adverse events assessed systematically of ECT versus rTMS: Tier 3, MDD and ≤ 20 percent bipolar disorder

Author, Year Design Outcome Scale Quality | Intervention and Sample Size Study Details | Adverse Events (Pain, Concentration, Sleep)
McLoughlin et al., 2007,^61^ Eranti et al., 2007,^62^ and Knapp et al., 2008^63^ RCT ECT CSSES modified Good | ECT (n = 24) 82% bilateral, mean session 6.3 (2.5) rTMS (n = 22) High frequency, 15 sessions | CSSES Baseline mean (SD) ECT: 14.2 (4.7) rTMS 13.2 (5.8) End of Treatment ECT: 6.7 (6.4) rTMS: 9.7 (4.6) At 6 months ECT: 7.1 (4.7) rTMS: 8.9 (4.7) Group effect P = 0.02 Group by time interaction, P = 0.49 No treatment-related major adverse events recorded during study (i.e., seizure induction, anesthetic complications, mania)

CCSES = Columbia Subjective Side Effects Schedule; ECT = electroconvulsive therapy; P = p-value; RCT = randomized controlled trial; rTMS = repetitive thranscranial magnetic stimulation

### Electroconvulsive Therapy Versus Electroconvulsive Therapy Plus Repetitive Transcranial Magnetic Stimulation

There were no eligible studies in Tier 2 or 3. In Tier 1, there was one eligible study in an MDD-only population and zero studies in an MDD/bipolar mix population.

#### Tier 1

There one study in an MDD-only population and no studies in an MDD/bipolar mix population.

Table 54 shows one study that compares ECT in 11 patients to ECT plus rTMS in another 11 patients.64 The ECT-only arm had more side effects numerically (P = NR) than the mixed arm, while differences between groups on specific side effects were not significant. The authors attribute the difference to the reduction in ECT treatments in the mixed group that had some rTMS instead of ECT.

Table 54 Adverse events assessed systematically of ECT versus ECT plus rTMS: Tier 1, MDD

Author, Year Design Outcome Scale Quality | Intervention and Sample Size Study Details | Adverse Events (Pain, Concentration, Sleep)
Pridmore et al., 2000^64^ RCT A six-item self-report side-effects questionnaire Fair | ECT (n = 11) 100% unilateral, 6 sessions ECT plus rTMS (n = 11) ECT: 100% unilateral (day 1), plus high frequency rTMS: (days 2-5) Repeated in week 2 | Positive side-effects questionnaire score ECT: 56 ECT plus rTMS: 31. P = NR Patients reporting side effects at week 2 Headache ECT: 9 ECT plus rTMS: 6 Muscle Pains ECT: 6 ECT plus rTMS: 4 Breathing problems, other pains, other problems (Data NR) For all comparisons, P = NS

CCSES = Columbia Subjective Side Effects Schedule; ECT = electroconvulsive therapy; NR = not reported; NS = not significant; RCT = randomized controlled trial; rTMS = repetitive thranscranial magnetic stimulation

#### Tier 2

There were no eligible studies.

#### Tier 3

There were no eligible studies.

### Repetitive Transcranial Magnetic Stimulation Versus Sham

Tier 1 consists of one RCT in patients with a diagnosis of MDD and no studies in patients with a mixed diagnosis of MDD/bipolar. In Tier 2 there were no eligible studies in the MDD-only population and two RCTs in an MDD/bipolar population. Within Tier 3, no eligible studies were identified.

#### Tier 1

There was one RCT in patients with a diagnosis of MDD and no studies in patients with a mixed diagnosis of MDD/bipolar.

##### MDD-Only

One RCT (N = 68) comparing high-frequency rTMS to sham used the SAFTEE (Systematic Assessment for Treatment Emergent Effects) instrument to measure adverse events, as seen in Table 55.^77,99^ The results showed no significant differences between rTMS and sham. Additionally it was reported that zero seizures occurred in subjects in both groups. However, the rTMS group experienced more occasions of scalp pain at the stimulation site at session one (41 percent) and session 15 (33 percent) than the sham group (0 and 3 percent, respectively).

Table 55 Adverse events assessed systematically of rTMS versus sham: Tier 1, MDD

Author, Year Design Outcome scale Quality | Intervention and Sample Size Study Details | Adverse Events (Pain, Concentration, Sleep)
Avery et al., 2006^77,99^ RCT SAFTEE Scores Good | rTMS (n = 35) High frequency, 15 sessions over 4 weeks Sham (n = 33) | SAFTEE Scores Scalp pain at the stimulation site,% Session 1: rTMS: 41 vs. sham: 0, P < 0.05 Session 15: rTMS: 33 vs. sham: 3, P < 0.05 Seizures, n: rTMS: 0 vs. sham: 0 Changes in SAFTEE (from baseline in 128 individual scores for any emerging symptoms that suggest adverse effects): rTMS vs. sham P = NS (Data = NR)

N = number; NS = not significant; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; SAFTEE = Systematic Assessment for Treatment Emergent Effects

##### MDD/Bipolar mix

There were no eligible studies.

#### Tier 2

There were two studies in the MDD-only population and two RCTs in an MDD/bipolar population.

##### MDD-Only

Table 56 contains the two studies that compare rTMS to sham.83,87,115,116,119,124,125 The first study used a modification of the Medical Dictionary for Regulatory Activities (MedRA) to code spontaneously reported adverse events. Adverse events recorded include headache, discomfort at stimulation site, insomnia, worsening of depression or anxiety, gastrointestinal, fatigue, muscle aches, vertigo, facial muscle twitching, and other. There were no statistical differences between rTMS and sham in the adverse events recorded.

Table 56 Adverse events assessed systematically of rTMS versus sham: Tier 2, MDD

Author, Year Design Outcome scale Quality | Intervention and Sample Size Study Details | Adverse Events
George et al., 2010^83^ RCT MedRA used Good | rTMS (n = 92) High frequency, 15 sessions Sham (n = 98) | Med RA Headache, discomfort at stimulation site, insomnia, worsening of depression or anxiety, gastrointestinal, fatigue, muscle aches, vertigo, facial muscle twitching, and other: No significant difference
O'Reardon et al., 2007,^87^ Janicak, 2007^*;115^ Solvason et al, 2007;^116^ Janicak et al., 2010;^119^ Demitrack et al., 2008^124^ Janicak et al., 2008^125^ RCT MedRA used Fair | rTMS (n = 165) High frequency, 20-30 sessions Sham (n = 160) | MedRA Exacerbation of depression, % rTMS:0.6 vs. sham:1.9 Eye pain, % rTMS: 6.1 vs. sham: 1.9 GI disorders toothache, % rTMS: 7.3 vs. sham: 0.6 Application site discomfort, % rTMS: 10.9 vs. sham: 1.3 Application site pain, % rTMS: 35.8 vs. sham: 3.8 Facial pain, % rTMS: 6.7 vs. sham: 3.2 Muscle twitching, % rTMS: 20.6 vs. sham: 3.2 Pain of skin, % rTMS: 8.5 vs. sham: 0.6] P = NR

GI = gastrointestinal; MedRA = Medical Dictionary for Regulatory Activities; n = number; NR = not reported; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; vs. = versus

* This study came from an unpublished source (conference proceeding).

The second study, as seen in Table 56, also used MedRA to record spontaneously reported adverse events. The following events occurred at a rate greater than 5 percent and occurred at least twice as much in the rTMS patients than sham: eye pain, toothache, application site discomfort, application site pain, facial pain, muscle twitching, and pain of skin. There were no statistical differences reported (P = NR).

##### MDD/Bipolar mix

Table 57 shows the two studies that compare rTMS to sham in Tier 2 patients diagnosed with MDD and bipolar disorder. One RCT reported no difference in trouble concentrating between rTMS and sham groups.88 This study also compared adverse events using a multiple-symptom “Side Effect Checklist.” Adverse events recorded include poor memory, nausea or vomiting, constipation, drowsiness, blurred vision, increased appetite, dry mouth, decreased appetite, tremors and shakiness, nightmares, difficulty sitting still, trouble concentrating, irregular or pounding heartbeat, diarrhea, frequent need to urinate, rash, ringing in the ears, sweating, faintness or lightheadedness, poor coordination, and muscle stiffness. Only one adverse event showed a significant difference between comparisons. “Difficulty starting urination” was reported significantly more often among the rTMS patients (2.0 vs. 1.1, P = 0.03) (Table 57).88

Table 57 Adverse events assessed systematically of rTMS versus sham: Tier 2, MDD and ≤ 20 percent bipolar disorder

Author, Year Design Outcome scale Quality | Intervention and Sample Size Study Details | Adverse Events (Pain, Concentration, Sleep)
Berman et al., 2000^88^ RCT SECL Fair | rTMS (n = 10) High frequency, 10 sessions Sham (n = 10) | SECL Headache, %: rTMS: 60 vs. sham: 50 P = NR Difficulty starting urination (ordinal scores from 0, none at all, to 3, severe): rTMS: 2.0 vs. sham: 1.1 P = 0.03 No significant difference between groups after correction for multiple comparisons (data NR)
Bretlau et al., 2008^89^ RCT UKU side effect scale Fair | rTMS (n = 25) High frequency, 15 sessions over 3 weeks Sham (n = 24) Both groups received 20 mg escitalopram | UKU side effect scale, mean scores Concentration difficulties: At week 3 rTMS: 1.43 vs. sham: 1.52 At week 12 rTMS: 0.71 vs. sham: 1.22 P < 0.05 Tension/inner unrest, tremor, akathisia, nausea, diarrhea, sweating, diminished sexual desire, headache, memory impairment, dry mouth, palpitations, and micturia: No significant difference between groups

mg = milligram; n = number; NR = not reported; P = p-value; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; SECL = Side Effect Checklist; UKU = Udvaig for Kliniske Undersogsler; vs. = versus

The other Tier 2 RCT (N = 49) compared rTMS with sham along with escitalopram (20 mg) in both groups and used the Udvaig for Kliniske Undersogsler (UKU) side-effect scale to assess side effects.89 Among the specific side effects assessed, they found no significant difference in headaches between groups. At 12-week followup, significantly more patients in the sham procedure group had difficulties concentrating than did rTMS patients (1.22 versus 0.71 on 0 to 3 scale, P < 0.05).

#### Tier 3

There were no eligible studies.

### Vagus Nerve Stimulation Versus Sham

There were no eligible studies in an MDD-only population and one study in an MDD/bipolar population in Tier 1. There were no eligible studies in Tiers 2 or 3.

#### Tier 1

There were no eligible studies in an MDD-only population and one study in an MDD/bipolar population.

##### MDD-Only

There were no eligible studies.

##### MDD/Bipolar mix

Table 58 shows a Tier 1 RCT (N = 235) that compared VNS versus sham.98 The study used the COSTART (Coding Symbols for Thesaurus of Adverse Reaction Terms) dictionary to assess adverse events. Many adverse events were listed, but no statistical analysis was conducted in the article. Numerous adverse events were more commonly reported in the VNS group than the sham group (P = NR). These included voice alteration (68% vs. 38%), cough increased (29% vs. 9%), dyspnea (23% vs. 14%), dysphasia (21% vs. 11%), and neck pain (21% vs. 10%) (for all P = NR). One participant underwent device explantation due to infection. Eleven patients (4 in VNS group and 7 in sham group) had worsening depression requiring hospitalization.

Table 58 Adverse events assessed systematically of VNS versus sham: Tier 1, MDD and ≤ 20 percent bipolar disorder

Author, Year Design Outcome scale Quality | Intervention and Sample Size Study Details | Adverse Events (Pain, Concentration, Sleep)
Rush et al., 2005^98^ RCT COSTART dictionary. Fair | VNS (n = 119) 10 weeks of VNS therapy with continued medications Sham (n = 116) | COSTART Dictionary (VNS vs sham)* Voice alteration (68% vs. 38%) Cough increased (29% vs. 9%) Dyspepna (23% vs. 14%) Dysphasia (21% vs. 11%) Neck pain (21% vs. 10%) Paresthesia (16% vs. 10%) Vomiting (11% vs. 5%) Laryngismus (11% vs. 2%) Dyspepsia (10% vs. 5%) Wound Infection (8% vs. 2%) Palpitations (8% vs. 2%) *article reports only AEs VNS ≥ 1.5 frequency of sham For all specific adverse events, P = NR Overall serious adverse events, n: VNS: 16 vs. sham: 14 (12 events in 11 patients [VNS: 4, sham: 7] were cases of worsening depression requiring hospitalization)

COSTART = Coding Symbols for Thesaurus of Adverse Reaction Terms; n = number; NR = not reported; P = p-value; RCT = randomized controlled trial; VNS = vagus nerve stimulation

#### Tier 2

There were no eligible studies.

#### Tier 3

There were no eligible studies.

## Key Question 4c Tolerability as Measured by Withdrawals due to Adverse Events—Overview

Withdrawals due to an adverse event illustrate the general tolerability of treatments for TRD. People who cannot tolerate the adverse effects of the treatments fall into this category. Overall, reporting of withdrawals due to adverse events was limited for some comparisons by the fact that no statistical significance was reported by the authors when withdrawals occurred.

Overall, 21 studies reported withdrawals due to adverse events (Table 59). When considering only studies conducted in TRD (Tier 1) MDD-only patients, we identified one head-to-head trial of ECT versus rTMS123 and four rTMS versus sham studies (five articles).69,71,76,77,99 In a Tier 1 MDD/bipolar population, we identified four studies that compared rTMS to sham18,74,80,81 and one study that compared VNS to sham.98

Table 59 Number of good- and fair-quality studies by TRD tier and diagnostic mix that assess withdrawals due to adverse events for KQ 4c

Comparison | Tier | MDD-Only | MDD and Bipolar Disorder
ECT vs. rTMS | Tier 1: ≥ 2 treatment failures | 1 | 0
ECT vs. rTMS | Tier 3: Probable | 0 | 2 additional
ECT vs. sham | Tier 3: Probable | 0 | 1 additional
rTMS vs. sham | Tier 1: ≥ 2 treatment failures | 4 | 4
rTMS vs. sham | Tier 2: ≥ 1 treatment failure | 3 additional | 0
rTMS vs. sham | Tier 3: Probable | 0 | 2 additional
VNS vs. sham | Tier 1: ≥ 2 treatment failures | 0 | 1
CBT vs. usual care | Tier 2: ≥ 1 treatment failure | 1 additional | 2 additional

CBT = cognitive behavioral therapy; ECT = electroconvulsive therapy; MDD = major depressive disorder; rTMS = repetitive transcranial magnetic stimulation; VNS = vagus nerve stimulation; vs. = versus

Additional eligible studies were found in Tiers 2 and 3. Three studies (8 articles) were conducted in Tier 2 patients with MDD comparing rTMS to sham.83,86,87,115,116,119,124,125 Two Tier 3 studies comparing rTMS versus sham in an MDD/bipolar mix population were identified.90,91 One Tier 2 study in patients with MDD94 and two Tier 2 studies in patients with an MDD/bipolar mix (three articles) compared CBT versus usual care.93,95,96 Two head-to-head studies (four articles) in Tier 3 compared ECT with rTMS61-63,126 and one study compared ECT to sham68 in a population diagnosed with MDD and bipolar disorder.

### Strength of Evidence: Tier 1 (TRD)

Few studies provide relevant data (Table 60). One small study showed no differences in withdrawals in ECT versus rTMS (statistical significance not reported), leading to a grade of low strength of evidence that withdrawals due to adverse events were greater with ECT than rTMS. In the rTMS versus sham group the results are mixed, with the data not providing a clear direction of effect of the treatment on withdrawals due to adverse events, resulting in a strength grade of insufficient. There was low strength of evidence that there were greater withdrawals due to adverse events in the vagus nerve stimulation group compared to sham.

Table 60 Strength of evidence: withdrawals due to adverse events -- Tier 1

Comparison | Number Of Studies; Subjects | Risk of Bias Design Quality | Consistency | Directness | Precision | Results and Strength of Evidence
ECT vs. rTMS | 1; 30 | Medium 1 fair prospective cohort study | Unknown | Direct | Imprecise | No differences between groups in ECT vs. rTMS P = NR Low
rTMS vs. sham | 7; 277 | Medium 7 RCTs 1 good, 6 fair | Inconsistent | Inirect | Imprecise | Mixed results Insufficient
VNS vs. sham | 1; 235 | Low RCT Good | Unknown | Indirect | Precise | More withdrawals due to AEs in the VNS group P = NR Low

AE = adverse event; ECT = electroconvulsive therapy; NR = not reported; P = p-value; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; VNS = vagus nerve stimulation; vs. = versus

## Key Question 4c Tolerability as Measured by Withdrawals Due to Adverse Events—Key Points

Withdrawals due to adverse events illustrate the general tolerability of treatments for treatment-resistant depression. Overall, reporting of withdrawals due to adverse events was limited by the fact that no tests of statistical significance were performed by the authors when withdrawals occurred.

## Key Question 4c Tolerability as Measured by Withdrawals Due to Adverse Events—Detailed Analysis

### Electroconvulsive Therapy Versus Repetitive Transcranial Magnetic Stimulation

Tier 1 consists of one prospective cohort study in an MDD population and none in an MDD/bipolar population (Table 61). Tier 2 has no eligible studies. Tier 3 has no studies in MDD-only patients and two RCTs in MDD/bipolar mix patients.

Table 61 Withdrawals due to adverse events of ECT versus rTMS: Tier 1, MDD

Author, Year Design Duration Quality | Intervention and Sample Size Study Details | Discontinuations During Treatment
Schulze-Rauschenbach et al., 2005^123^ Prospective cohort 1 week (post-test measurement 8.8 days after txt) Fair | ECT (n = 14) Right unilateral txt for 2 weeks rTMS (n = 16) High frequency, mean 10.8 sessions (SD 1.4) | Due to AEs, n (%): ECT: 1 (7.1) rTMS: 0 (0) P = NR

AE = adverse event; ECT = electroconvulsive therapy; NR = not reported; P = p-value; SD = standard deviation; rTMS = repetitive transcranial magnetic stimulation; txt = treatment

#### Tier 1

There was one prospective cohort study in an MDD population and none in an MDD/bipolar population.

##### MDD-Only

One fair-quality prospective cohort study123 adequately reported withdrawals due to adverse events. This observational study reported greater withdrawals in the ECT versus rTMS group (7.1% versus 0%, respectively).123 Sample sizes were small, all with less than 20 patients per study arm (Table 61).

##### MDD/Bipolar mix

There were no eligible studies.

#### Tier 2

There were no eligible studies.

#### Tier 3

There were no studies in MDD-only patients and two RCTs in MDD/bipolar mix patients.

##### MDD-Only

There were no eligible studies.

##### MDD/Bipolar mix

Two RCTs (four articles, one good-quality and one fair-quality).61-63,126 They reported no withdrawals due to adverse events (Table 62).

Table 62 Withdrawals due to adverse events of ECT versus rTMS: Tier 3, MDD and ≤ 20 percent bipolar disorder

Author, Year Design Duration Quality | Intervention and Sample Size Study Details | Discontinuations During Treatment
McLoughlin et al., 2007,^61^ Eranti et al., 2007,^62^ and Knapp et al., 2008^63^ RCT 3 weeks Good | ECT (n = 24) 82% bilateral, mean sessions 6.3 (SD 2.5) rTMS (n = 22) High frequency, 15 sessions | Due to AEs: 0
O'Connor, 2003^126^ Prospective cohort Up to 4 weeks Fair | ECT (n = 14) Unilateral, 3 times per week for 2 to 4 weeks rTMS (n = 14) High frequency, 10 sessions | Due to AEs: 0

AE = adverse event; ECT = electroconvulsive therapy; n = number; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation

### Electroconvulsive Therapy Versus Sham

Tier 1 has no eligible studies (Table 63). Tier 2 has no eligible studies. Tier 3 has no studies in MDD-only patients and one RCT in MDD/bipolar mix patients.

Table 63 Withdrawals due to adverse events of ECT versus rTMS: Tier 3, MDD and ≤ 20 percent bipolar disorder

Author, Year Design Duration Quality | Intervention and Sample Size Study Details | Discontinuations During Treatment
Johnstone et al., 1980^68^ RCT 3 weeks Fair | ECT (n = 35) Bilateral, 8 sessions Sham (n = 35) | Due to AEs (%): ECT: 5.7 Sham: 0 P = NR

AE = adverse event; ECT = electroconvulsive therapy; n = number; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation

#### Tier 1

There were no eligible studies.

#### Tier 2

There were no eligible studies.

#### Tier 3

There were no studies in MDD-only patients and one RCT in MDD/bipolar mix patients (Table 63).

##### MDD-Only

There were no eligible studies.

##### MDD/Bipolar mix

One study in a population with “severe endogenous depression” referred for ECT.68 Withdrawals due to adverse events were 5.7 percent in the ECT arm and 0 in the simulated ECT arm (see Table 63).

### Repetitive Transcranial Magnetic Stimulation Versus Sham

Tier 1 contains four RCTs in patients with MDD-only (Table 64) and three RCTs in MDD/bipolar patients (Table 65). There are three RCTs in an MDD-only population and no eligible studies in MDD/bipolar diagnosis patients in Tier 2. In Tier 3 there were no studies in MDD-only patients and two RCTs in patients with an MDD/bipolar mix diagnosis.

Table 64 Withdrawals due to adverse events of rTMS versus sham: Tier 1, MDD

Author, Year Design Duration Quality | Intervention and Sample Size Study Details | Discontinuations During Treatment
Avery et al., 2006^77^ and Avery et al., 2007^99^ RCT 4 weeks Good | rTMS (n = 35) High frequency, 15 sessions Sham (n = 33) | Due to AEs: 0
Boutros, et al., 2002^69^ RCT 2 weeks Fair | rTMS (n = 12) High frequency, 10 sessions Sham (n = 9) | Due to AEs: 0
Garcia-Toro et al., 2006^71^ RCT 2 weeks Fair | rTMS-1 (n = 10) High frequency plus low frequency, 10 sessions rTMS-2 (n = 10) Same as above with individually assessed location Sham: (n = 10) | Due to AEs: 0
Holtzheimer et al., 2004^76^ RCT 2 weeks Fair | rTMS (n = 7) High frequency, 10 sessions Sham (n = 8) | Due to AEs: 0

AE = adverse event; n = number; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation

Table 65 Withdrawals due to adverse events of rTMS versus sham: Tier 1, MDD and ≤ 20 percent bipolar disorder

Author, Year Design Duration Quality | Intervention and Sample Size Study Details | Discontinuations During Treatment
Fitzgerald et al., 2006^18^ RCT 6 weeks Fair | High plus low rTMS (n = 25) High-frequency rTMS up to 30 sessions plus low-frequency rTMS up to 30 sessions Sham (n = 25) | Due to AEs: 0
Fitzgerald et al., 2003^80^ RCT Phase I: 2 weeks Fair | High rTMS (n = 20) High frequency, 10 sessions Low rTMS (n = 20) Low frequency, 10 sessions Sham (n = 20) | Due to AEs: 0
Pallanti et al., 2010{#2551} RCT 3 weeks Fair | Low plus High rTMS (n = 20) Low then high frequency, 15 sessions rTMS (n = 20) Low frequency, 15 sessions Sham (n = 20) | Due to AEs, n (%): Low plus high rTMS: 0 (0) Low rTMS: 0 (0) Sham: 0 (0) P = NR
Su et al., 2005^81^ RCT 2 weeks Fair | 20 Hz rTMS (n = 11) High frequency (20 Hz), 10 sessions 5 Hz rTMS (n = 11) High frequency (5 Hz),10 sessions Sham (n = 11) | Due to AEs, %: All rTMS: 9.1 20 Hz rTMS: 0 5 Hz rTMS: 17 Sham: 0 P = NR

AE = adverse event; Hz = hertz; n = number; RCT = randomized controlled trial, rTMS = repetitive transcranial magnetic stimulation

#### Tier 1

There are three RCTs in patients with MDD-only and four RCTs in MDD/bipolar patients.

##### MDD-Only

Table 64 presents one good and three fair RCTs that reported no withdrawals in either patients treated with rTMS or sham.69,71,76,77,99

##### MDD/Bipolar mix

Four fair RCTs reported withdrawals due to adverse events in patients previously treated two or more times for depression, as seen in Table 65. Three of the studies showed no withdrawals due to adverse events.18,74,80 There was one study that showed a difference in withdrawals due to adverse events (rTMS 9.1% versus none for sham).81 There are important differences between this study and the others in this group, primarily in the strength of the intervention. As can be seen, the RCT that showed differences in withdrawals due to adverse events used more pulses per session, 1,600 versus 750 to 1,000 and 20 Hz versus 10 Hz, which could explain the differences in withdrawals due to adverse events within this group.

#### Tier 2

There are three RCTs in an MDD-only population and no eligible studies in MDD/bipolar diagnosis patients (Table 66).

Table 66 Withdrawals due to adverse events of rTMS versus sham: Tier 2, MDD

Author, Year Design Duration Quality | Intervention and Sample Size Study Details | Discontinuations During Treatment
George et al., 2010^83^ RCT 3 weeks of txt Good | rTMS (n = 92) High frequency, 15 sessions Sham (n = 98) | Due to AEs, %: rTMS: 5.4 Sham: 0 P = NR
O'Reardon, 2007,^87^ Janicak, 2007^115^ and Solvason, 2007^116^ Janciak et al., 2008^125^ and Janicak et al., 2010^119^ RCT 4 weeks primary endpoint Fair | rTMS (n = 165) High frequency, 20-30 sessions Sham (n = 160) | Due to AEs, %: rTMS: 4.2 Sham: 3.4 P = NR
Stern et al., 2007^86^ RCT 2 weeks of txt Fair | High rTMS (n = 10) High frequency, 10 sessions Low-left rTMS (n = 10) Low frequency (Left-DLPFC), 10 sessions Low rTMS (n = 10) Low frequency, 10 sessions Sham (n = 15) | Due to AEs, %: High rTMS: 0 Low-left rTMS: 50 Low rTMS: 0 Sham: 20 P = NR

AE = adverse event; DLPFC = dorsolateral prefrontal cortex; n = number; NR = not reported; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; txt = treatment

##### MDD-Only

One relatively large (n = 325) study compared Tier 2 patients in an MDD-only population.87,115,116,119,124,125 The withdrawals due to adverse events were similar in the rTMS group (4.2%) versus sham (3.4%) over the 4-week time period. Another decent size study (N = 190) compared withdrawals due to adverse events between rTMS at 5.4 percent to sham at 0 percent.83 Additionally a small study (n = 45) compared withdrawals due to adverse events in four arms, high rTMS (n = 10), low-left rTMS (n = 10), low rTMS (n = 10) and sham (n = 15).86 Two arms had no withdrawals but the low-left rTMS had 50 percent withdrawals due to adverse event rate and 30 percent in the sham group.

##### MDD/Bipolar mix

There were no eligible studies.

#### Tier 3

There were no studies in MDD-only patients and two RCTs in patients with an MDD/bipolar mix diagnosis (Table 67).

Table 67 Withdrawals due to adverse events of rTMS versus sham: Tier 3, MDD and ≤ 20 percent bipolar disorder

Author, Year Design Duration Quality | Intervention and Sample Size Study Details | Discontinuations During Treatment
Bortolomasi et al., 2006^90^ RCT 1 week Fair | rTMS (n = 12) High frequency, 5 sessions Sham (n = 7) | Due to AEs: 0
George et al., 1997^91^ RCT, crossover Primary endpoint after 2 weeks of txt Fair | rTMS (n = 12) High frequency, 10 sessions Sham (n = 12) | Due to AEs: 0

AE = adverse event; n = number; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; txt = treatment

##### MDD-Only

There were no eligible studies.

##### MDD/Bipolar mix

There were two small studies (n = 19 and 24) in a Tier 3 MDD/bipolar mix population comparing rTMS to sham.90,91 Neither had any withdrawals due to adverse events.

### Vagus Nerve Stimulation Versus Sham

There were no eligible studies in patients with MDD-only and one RCT in patients with an MDD/bipolar diagnosis in Tier 1. In Tiers 2 and 3, there were no eligible studies.

#### Tier 1

There were no eligible studies in patients with MDD-only and one RCT in patients with an MDD/bipolar mix diagnosis (Table 68).

Table 68 Withdrawals due to adverse events of VNS versus sham: Tier 1, MDD and ≤ 20 percent bipolar disorder

Author, Year Design Duration Quality | Intervention and Sample Size Study Details | Discontinuations During Treatment
Rush et al., 2005^98^, RCT 10 weeks Good | VNS (n = 112) 10 weeks of VNS therapy with continued medications Sham (n = 110) | Due to AEs, %: VNS: 2.7 Sham: 0 P = NR

AE = adverse event; n = number; NR = not reported; P = p-value; RCT = randomized controlled trial; VNS = vagus nerve stimulation

##### MDD-Only

There were no eligible studies.

##### MDD/Bipolar mix

One good-quality RCT (N = 222) comparing VNS to sham-control in a Tier 1 population reported 2.7 percent withdrawals due to adverse events in the VNS group compared with none in the sham-control group over a 10-week treatment period.98

#### Tier 2

There were no eligible studies.

#### Tier 3

There were no eligible studies.

### Cognitive Behavioral Therapy Versus Usual Care

There were no eligible studies in Tier 1. In an MDD population there was one eligible study and 2 studies in an MDD/bipolar mix population in Tier 2. There were no eligible studies in Tier 3.

#### Tier 1

There were no eligible studies.

#### Tier 2

There was one study in MDD-only and 2 studies in patients with an MDD/bipolar mix.

##### MDD-Only

One RCT reported withdrawals due to adverse events in 491 patients randomized to either medication alone or medication plus psychotherapy over 12 weeks of treatment (Table 69).94 The medication-alone arm had 2.1 percent versus 0.8 percent withdrawals in the medication plus psychotherapy due to adverse events.

Table 69 Withdrawals due to adverse events of CBT versus sham: Tier 2, MDD

Author, Year Design Duration Quality | Intervention and Sample Size Study Details | Discontinuations During Treatment
Kocsis et al., 2009^94^ RCT 12 weeks Fair | CBT plus medication (n =395) Cognitive behavioral analysis system of psychotherapy (n = 200) 16-20 sessions; brief supportive psychotherapy (n = 195) 16-20 sessions Medication only (n=96) | Due to AEs: CBT plus medication: 3 (0.8%) Medication only: 2 (2.1%) P = NR

AE = adverse event; CBT = cognitive behavioral therapy; n = number; RCT = randomized controlled trial

##### MDD/Bipolar mix

Two RCTs (four articles, one good-quality, one fair-quality) comparing CBT to some form of usual care reported no withdrawals due to adverse events, as shown in Table 70.^93,95,96,120^ These studies ranged in duration from 16 weeks of treatment to 12-month followup periods.

Table 70 Withdrawals due to adverse events of rTMS versus sham: Tier 2, MDD and ≤ 20 percent bipolar disorder

Author, Year Design Duration Quality | Intervention and Sample Size Study Details | Discontinuations During Treatment
Harley, 2008^93^ RCT 16 weeks Fair | CBT ([DBT] (n = 13) 16-sessions of dialectical behavior therapy skill training Control (n = 11) Waitlist | Due to AEs: 0
Paykel, 1999,^95^ Scott, 2000,^96^ and Scott, 2003^120^ RCT 20 weeks Good | Cognitive Therapy (n = 80) 16 sessions of cognitive therapy plus clinical management Clinical Management (n = 78) Clinical management – patients visited psychiatrist every 4 weeks and continued on current medication | Due to AEs: 0

AE = adverse event; CBT = cognitive behavioral therapy; n = number; RCT = randomized controlled trial

#### Tier 3

There were no eligible studies.

## Key Question 4d Adherence as Measured by Overall Withdrawals—Overview

Of 64 included studies, two studies reporting compliance indicated a 100 percent rate66,71 and 1 reported a 63 percent adherence rate.83 Overall withdrawals were used as a proxy to capture compliance as it was recorded more frequently. Out of the 64 included studies, 26 studies (32 articles) reported total withdrawals (for any reason) during treatment (Table 71).

Table 71 Number of good- and fair-quality studies by TRD tier and diagnostic mix that assess overall withdrawals for KQ 4d

Comparison | Tier | MDD-Only | MDD and Bipolar Disorder
ECT vs. rTMS | Tier 1: ≥ 2 treatment failures | 2 | 0
ECT vs. rTMS | Tier 3: Probable | 0 | 3 additional
ECT vs. sham | Tier 3: Probable | 1 additional | 1 additional
rTMS vs. sham | Tier 1: ≥ 2 treatment failures | 4 | 3
rTMS vs. sham | Tier 2: ≥ 1 treatment failure | 3 additional | 2 additional
rTMS vs. sham | Tier 3: Probable | 0 | 2 additional
CBT vs. usual care | Tier 2: ≥ 1 treatment failure | 2 additional | 2 additional

CBT = cognitive behavioral therapy; ECT = electroconvulsive therapy; rTMS = repetitive transcranial magnetic stimulation; vs. = versus

When considering only studies conducted in Tier 1 patients with MDD, there were two head-to-head trials of ECT versus rTMS58,123 and three rTMS versus sham studies (four articles).71,76,77,99 There were five Tier 1 studies, conducted in an MDD/bipolar population that compared rTMS to sham.18,69,80-82

Additional eligible studies were found in Tiers 2 and 3. In Tier 2 MDD-only populations, we identified three studies (eight articles) comparing rTMS to sham83,86,87,115,116,119,124,125 and two studies in an MDD/bipolar mix population.88,89 We also identified two studies in MDD-only populations comparing CBT to usual care.94,102 In Tier 2 MDD/bipolar mix populations, we identified two studies (three articles) comparing CBT versus usual care.93,95,96 Three head-to-head studies (four articles) in Tier 3 compared ECT with rTMS in a population diagnosed with MDD and bipolar disorder.60-63,126 There are two Tier 3 studies that compared ECT to sham, one in an MDD-only group67 and one in an MDD and bipolar population.68 There are also two Tier 3 studies that compared rTMS to sham in a MMD and bipolar population.90,91

### Strength of Evidence: Tier 1 (TRD)

The data addressing overall withdrawals (Table 72) for ECT versus rTMS showed greater withdrawals in ECT when compared with rTMS (P = NR). For rTMS versus sham, mixed results were found. Strength of evidence is low for ECT versus rTMS and insufficient for rTMS versus sham.

Table 72 Strength of evidence: overall withdrawals during treatment -- Tier 1

Comparison | Number Of Studies; Subjects | Risk of Bias Design Quality | Consistency | Directness | Precision | Results and Strength of Evidence
ECT vs. rTMS | 2; 72 | Medium 1 fair RCT 1 fair prospective cohort study | Consistent | Direct | Imprecise | ECT group had higher number of withdrawals P = NR Low
rTMS vs. sham | 8; 325 | Medium 8 RCTs 1 good 7 fair | Inconsistent | Indirect | Imprecise | Mixed results Insufficient

ECT = electroconvulsive therapy; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; vs. = versus

## Key Question 4d Adherence as Measured by Overall Withdrawals—Key Points

Of the 27 studies with relevant data, there were only three studies (three articles) that assessed adherence or compliance during treatment.66,71,83 Two reported that all patients completed all required treatments as specified in the protocol and one reported an overall adherence rate of 62 to 64 percent. As a proxy to explore adherence, we chose overall withdrawals, which are found in 10 Tier 1 studies and an additional 15 studies in Tiers 2 and 3.

Overall, reporting of withdrawals during treatment was limited by the fact that statistical significance was not reported. Studies were generally small and unlikely to have had power to show statistical or clinical significance, methods varied, and there was significant heterogeneity across the populations studied.

## Key Question 4d Adherence as Measured by Overall Withdrawals—Detailed Analysis

As shown in Table 73, there were only three studies that reported adherence or compliance.66,71,83 Two of them reported 100 percent compliance and one reported adherence of 62 to 64 percent.

Table 73 Adherence/compliance for all comparable interventions: all tiers

Author, Year Design Duration Tier Quality | Intervention and Sample Size Study Details | Results
Folkerts et al.66 RCT: patient status NR 4 weeks Tier 1 Fair | ECT (n = 21) Right unilateral, mean txts = 7.2 sessions (2-3 weeks) Pharmacotherapy (n = 18) Paroxetine 40 mg (max 50 mg/d, mean daily dosage 44 mg/day | All patients continued their respective therapies through scheduled end of treatment phase
Garcia-Toro et al., 2006^71^ RCT: outpatient 2 weeks Tier 1 Fair | rTMS-1 (n = 10) High frequency plus low frequency, 10 sessions rTMS-2 (n = 10) Same as above but with individually assessed location Sham: (n = 10) | All completed 10 rTMS sessions
George et al., 2010^83^ RCT Tier 2 Good | rTMS (n = 92) High frequency, 15 sessions Sham (n = 98) | Fully adherent to treatment, % rTMS: 62 Sham: 64

ECT = electroconvulsive therapy; mg/day = milligram per day; n = number; NR = not reported; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; txt = treatment

### Electroconvulsive Therapy Versus Repetitive Transcranial Magnetic Stimulation

There were two studies, an RCT and a prospective cohort study, in Tier 1. There were no eligible studies in Tier 2; in Tier 3 there were no MDD studies, and in an MDD/bipolar mix there were two RCTs and one prospective cohort study.

#### Tier 1

There were two studies, an RCT and a prospective cohort study.

##### MDD-Only

There are two Tier 1 studies that compared ECT to rTMS and reported overall withdrawals, as seen in Table 74. The first is a small RCT (n = 42) that resulted in more withdrawals in the ECT group of 15.1 percent than the rTMS group at 9.1 percent (P = NR).58 The second study was a small prospective cohort study (N = 30).123 Similar to the RCT, it showed that the ECT group experienced higher overall withdrawals of 7.1 percent versus 0 percent in the rTMS group, but significance is not reported.

Table 74 Overall withdrawals of ECT versus rTMS: Tier 1, MDD

Author, Year Design Duration Quality | Intervention and Sample Size Study Details | Results
Rosa et al., 2006^58^ RCT Up to 4 weeks Fair | ECT (n = 20) % bilateral NR, mean sessions: 10 (SD 1.5) rTMS (n = 22) High frequency, 10-20 sessions (2-4 weeks) | Overall, %: ECT: 15.0 rTMS: 9.1 P = NR
Schulze-Rauschenbach et al., 2005^123^ Prospective cohort 1 week (post-test measurement 8.8 days after txt) Fair | ECT (n = 14) Right unilateral treatment for 2 weeks, mean # sessions 9.9 (SD 2.7) rTMS (n = 16) High frequency, mean sessions: 10.8 (SD 1.4) | Overall, %: ECT: 7.1 rTMS: 0 P = NR

ECT = electroconvulsive therapy; n = number; NR = not reported; P = p-value; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation; txt = treatment

##### MDD/Bipolar mix

There were no eligible studies.

#### Tier 2

There were no eligible studies.

#### Tier 3

There were no MDD studies and in an MDD/bipolar mix there were two RCTs and one prospective cohort study.

##### MDD-Only

There were no eligible studies.

##### MDD/Bipolar mix

As shown in Table 75, three studies report overall withdrawals in a Tier 3 population comparing ECT to rTMS. A good-rated RCT reported overall withdrawals in the ECT group of 0 percent compared to 25 percent in the rTMS arm (P = NR).61-63 Another RCT reported overall withdrawals in the ECT group of 26.7 percent compared to 33.3 percent in the rTMS arm.60A small prospective cohort reported no overall withdrawals in either arm.126

Table 75 Overall withdrawals of ECT versus rTMS: Tier 3, MDD and ≤ 20 percent bipolar disorder

Author, Year Design Duration Quality | Intervention and Sample Size Study Details | Withdrawals during treatment
McLoughlin et al., 2007,^61^ Eranti et al., 2007,^62^ and Knapp et al., 2008^63^ RCT 3 weeks Good | ECT (n = 24) 82% bilateral, mean sessions: 6.3 (SD 2.5) rTMS (n = 22) High frequency, 15 sessions | Overall, % ECT: 0 rTMS: 25 P = NR
Hansen, 2010^60^ RCT 3 weeks Fair | ECT (n = 30) 100% unilateral, 9 sessions rTMS (n = 30) Low frequency, 15 sessions | Overall, % ECT: 26.7 rTMS: 33.3 P = NR
O'Connor, 2003^126^ Prospective cohort Up to 4 weeks Fair | ECT (n = 14) Unilateral, 3 times per week for 2 to 4 weeks rTMS (n = 14) High frequency, 10 sessions | Overall: 0

ECT = electroconvulsive therapy; n = number; NR = not reported; P = p-value; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation

### Electroconvulsive Therapy Versus Sham

Tier 1 has no eligible studies (Table 76). Tier 2 has no eligible studies. Tier 3 has one study in MDD-only patients and one RCT in MDD/bipolar mix patients.

Table 76 Withdrawals due to adverse events of ECT versus sham: Tier 3, MDD

Author, Year Design Duration Quality | Intervention and Sample Size Study Details | Discontinuations During Treatment
West, 1981^67^ RCT Up to 3 weeks Fair | ECT (n = 13) Bilateral, 6 sessions Sham (n = 12) | Overall withdrawals (%): ECT: 15.4 Sham: 8.3 P = NR

ECT = electroconvulsive therapy; n = number; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation

#### Tier 1

There were no eligible studies.

#### Tier 2

There were no eligible studies.

#### Tier 3

Two trials comparing ECT with sham stimulation were identified in Tier 3.

##### MDD-Only

There was one study, in Table 76, in a population with “primary depressive illness” referred for ECT.67 Overall withdrawals were recorded as 15.4 percent in the ECT group versus 8.3 percent in the simulated ECT group (P = NR).

##### MDD/Bipolar mix

There was one study, shown in Table 77, in a population with “severe endogenous depression” referred for ECT.68 Overall withdrawals were recorded as 11.4 percent in the ECT group and 11.4 percent in the simulated ECT group (P = NR).

Table 77 Withdrawals due to adverse events of ECT versus sham: Tier 3, MDD and and ≤ 20 percent bipolar disorder

Author, Year Design Duration Quality | Intervention and Sample Size Study Details | Discontinuations During Treatment
Johnstone et al., 1980^68^ RCT 3 weeks Fair | ECT (n = 35) Bilateral, 8 sessions Sham (n = 35) | Overall withdrawals (%): ECT: 11.4 Simulated ECT: 11.4 P = NR

ECT = electroconvulsive therapy; n = number; NR = not reported; P = p-value; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation.

### Repetitive Magnetic Stimulation Versus Sham

Tier 1 contains four RCTs in patients with MDD-only and three RCTs in MDD/bipolar patients. There are three RCTs in an MDD-only population and two eligible studies in an MDD/bipolar population in Tier 2. In Tier 3 there were no studies in MDD-only patients and two RCTs in patients with an MDD/bipolar mix population.

#### Tier 1

##### MDD-Only

There are four RCTs that compare overall withdrawals in rTMS versus sham in a Tier 1 population (see Table 78). Two report that there are no withdrawals in either the rTMS or sham arms.71,76 An RCT conducted in 68 patients showed an overall withdrawal rate of 9.1 percent in the rTMS arm and 8.6 percent in the sham arm (P = NR).77,99 Another RCT of 21 patients had overall withdrawals of 8.3 percent in the rTMS group and 30.0 in the sham group.69

Table 78 Overall withdrawals of rTMS to sham: Tier 1, MDD

Author, Year Design Duration Quality | Intervention and Sample Size Study Details | Results
Avery et al., 2006^77,99^ RCT 4 weeks Good | rTMS (n = 35) High frequency, 15 sessions Sham (n = 33) | Overall, %: rTMS: 9.1 Sham: 8.6 P = NR
Boutros, et al., 2002^69^ RCT 2 weeks Fair | rTMS (n = 12) High frequency, 10 sessions Sham (n = 9) | Overall, %: rTMS: 8.3 Sham: 30.0 P = NR
Garcia-Toro et al., 2006^71^ RCT 2 weeks Fair | rTMS-1 (n = 10) High frequency plus low frequency, 10 sessions rTMS-2 (n = 10) Same as above but with individually assessed location Sham: (n = 10) Double winged coil angled at 45 degrees | Overall: 0
Holtzheimer et al., 2004^76^ RCT 2 weeks Fair | rTMS (n = 7) High frequency, 10 sessions Sham (n = 8) | Overall: 0

n = number; NR = not reported; P = p-value; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation

##### MDD/Bipolar mix

Four RCTs comprise the MDD/bipolar mix in a Tier 1 population, as shown in Table 79. One RCT conducted in 40 patients had zero withdrawals in any arm.80 Another RCT with 48 patients also had zero withdrawals.82 Another small study (N = 33) had 9.1 percent overall withdrawals in the rTMS and sham groups.81 A larger study, 50 patients, had 0 percent overall withdrawals in the rTMS group and 12 percent in the sham group.18

Table 79 Overall withdrawals of rTMS to sham: Tier 1, MDD and ≤ 20 percent bipolar disorder

Author, Year Design Duration Quality | Intervention and Sample Size Study Details | Results
Fitzgerald et al., 2006^18^ RCT 6 weeks Fair | High plue Low rTMS (n = 25) High frequency plus low frequency, up to 30 sessions Sham (n = 25) | Overall, %: rTMS: 0 Sham: 12 P = NR
Fitzgerald et al., 2003^80^ RCT Phase I: 2 weeks Phase II: NA Fair | High rTMS (n = 20) High frequency, 10 sessions Low rTMS (n = 20) Low frequency, 10 sessions Sham (n = 20) | Overall: 0
Su et al., 2005^81^ RCT 2 weeks Fair | 20 Hz rTMS (n = 11) High frequency (20 Hz), 10 sessions 5 Hz rTMS (n = 11) High frequency (5 Hz),10 sessions s Sham (n = 11) | Overall, % 10 Hz rTMS and 5 Hz rTMS: 9.1 Sham: 9.1 P = NR
Triggs et al., 2010^82^ RCT 2 weeks Fair | High rTMS (n = 18) High frequency, 10 sessions High right rTMS (n = 16) High frequency to the right prefrontal cortex, 10 sessions Sham left (n = 7) Sham right (n = 7) NOTE: Patients in all groups also received a social support intervention | Overall: 0

Hz = Hertz; n = number; NR = not reported; P = p-value; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation

#### Tier 2

##### MDD-Only

There were three RCTs in Tier 2 in MDD-only patients, as seen in Table 80. A relatively large study, 325 patients, had overall withdrawals of 13.3 percent in the rTMS arm and 16.3 percent in the sham arm.87,115,116,119,124,125 The second study, conducted with 190 patients, had overall withdrawals of 12 percent in the rTMS arm and 9 percent in the sham arm.83 A small study (n = 45) compared overall withdrawals in four arms, high rTMS (n = 10), low-left rTMS (n = 10), low-right rTMS (n = 10), and sham (n = 15). Two arms had no withdrawals but the low-left rTMS had a 20 percent overall withdrawal rate and 6.7 percent in the sham group.86

Table 80 Overall withdrawals of rTMS to sham: Tier 2, MDD

Author, Year Design Duration Quality | Intervention and Sample Size Study Details | Results
George et al., 2010^83^ RCT Up to 6 weeks of txt Good | rTMS (n = 92) High frequency, 15 sessions Sham (n = 98) | Overall, % rTMS: 12 Sham: 9 P = NR
O'Reardon, 2007^87,115,116,119,124,125^ RCT 4 weeks primary endpoint Fair | rTMS (n = 165) High frequency, 20-30 sessions Sham (n = 160) | Overall, % rTMS: 13.3 Sham: 16.3 P = NR
Stern et al., 2007^86^ RCT 2 weeks of txt Fair | High rTMS (n = 10) High frequency, 10 sessions Low-left rTMS (n = 10) Low frequency, (1 Hz), Left DLPFC, 10 sessions Low rTMS (n = 10) Low frequency, 10 sessions Sham (n = 15) | Overall: High rTMS: 0 Low-left rTMS: 20 Low rTMS: 0 Sham: 6.7 P = NR

DLPFC = dorsolateral prefrontal cortex; n = number; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; txt = treatment

##### MDD/Bipolar mix

Table 81 provides the two studies that were found in a Tier 2 MDD/bipolar population.88,89 Overall withdrawals were 0 percent in the rTMS arm and 30 percent in the sham arm. However, no significance was reported.88 The final study in this group had overall withdrawals of 12.0 percent in the rTMS arm versus 4.2 percent but significance is not reported.89

Table 81 Overall withdrawals of rTMS to sham: Tier 2, MDD and and ≤ 20 percent bipolar disorder

Author, Year Design Duration Quality | Intervention and Sample Size Study Details | Results
Berman et al, 2000^88^ RCT 2 weeks Fair | rTMS (n = 10) High frequency, 10 sessions Sham (n = 10) | Overall: rTMS: 0 Sham: 30 P = NR
Bretlau et al., 2008^89^ RCT 3 weeks Fair | rTMS (n = 25) High frequency, 15 sessions over 3 weeks Sham (n = 24) Both groups received 20 mg escitalopram | Overall, %: rTMS: 12.0 Sham: 4.2 P = NR

mg = milligram; n = number; NR = not reported; P = p-value; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation

#### Tier 3

There were no studies in MDD-only patients and two RCTs in patients with an MDD/bipolar mix diagnosis.

##### MDD-Only

There were no eligible studies.

##### MDD/Bipolar mix

Two small studies, 19 and 24 patients, compared rTMS and sham in Tier 3 subjects, as seen in Table 82.^90,91^ Neither of these studies had any overall withdrawals.

Table 82 Overall withdrawals of rTMS to sham: Tier 3, MDD and ≤ 20 percent bipolar disorder

Author, Year Design Duration Quality | Intervention and Sample Size Study Details | Results
Bortolomasi et al., 2006^90^ RCT 1 week Fair | rTMS (n = 12) High frequency, 5 sessions Sham (n = 7) | Overall: 0
George et al., 1997^91^ RCT, crossover Primary endpoint after 2 weeks of txt Fair | rTMS (n = 12) High frequency, 10 sessions Sham (n = 12) | Overall: 0

N = number; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; txt = treatment

### Cognitive Behavioral Therapy Versus Usual Care

There were no eligible studies in Tier 1. Tier 2 had two studies in patients with MDD-only and two studies in patients diagnosed with MDD/bipolar mix; there were no eligible studies in Tier 3.

#### Tier 1

There were no eligible studies.

#### Tier 2

There were two studies in patients with MDD-only and two studies in patients diagnosed with MDD/bipolar mix.

##### MDD-Only

Table 83 provides two studies, one small study of 32 patients102 and one larger study of 491 patients,94 conducted in MDD-only Tier 2 patients. In the smaller study, the overall withdrawal rate was 16.7 percent in the CBT arm and 42.9 percent in the usual care arm. Statistical significance was not reported; the CBT arm had 26 subjects compared to 6 in the usual care arm. The larger study had overall withdrawals of 16.6 percent in the medication arm and 13.2 percent in the medication plus psychotherapy arm (P = NR).

Table 83 Overall withdrawals of CBT versus medication: Tier 2, MDD

Author, Year Design Duration Quality | Intervention and Sample Size Study Details | Results
Kocsis et al., 2009^94^ RCT 12 weeks Fair | CBT plus medication (n =395) Cognitive behavioral analysis system of psychotherapy (n = 200); 16-20 sessions; brief supportive psychotherapy (n = 195) 16-20 sessions Medication only (n=96) | Overall, % CBT plus medication: 13.2 Medication: 16.6 P = NR
Moore et al., 1997^102^ RCT Active phase occurred during 12-month followup phase Fair | CBT (n = 26) Minimum of 4 treatments in 1st month, 2 treatments in 2nd month, and 1 per month following Medication (n = 6) Continued or new medication dose within recognized therapeutic threshold | Overall, % CBT: 16.7 Medication: 42.9 P = NR

CBT = cognitive behavioral therapy; n = number; NR = not reported; P = p-value; RCT = randomized controlled trial

##### MDD/Bipolar mix

Two studies (four articles) compared CBT to usual care with mixed results in patients with MDD/bipolar mix in Tier 2 (see Table 84). The smaller one, 24 patients, had an overall withdrawal rate of 23.1 percent in the CBT arm and 18.2 percent in the waitlist control arm.93 A larger study, 158 patients, had overall withdrawals of 15.4 percent in the CBT arm versus 23.8 percent in the usual care arm.95,96,120 For either study, statistical significance was not reported.

Table 84 Overall withdrawals of CBT versus usual care: Tier 2, MDD and ≤ 20 percent bipolar disorder

Author, Year Design Quality | Intervention and Sample Size Study Details | Results
Harley, 2008^93^ RCT 16 weeks Fair | CBT [DBT] (n = 13) 16-session, once-weekly group covered the 4 dialectical behavior therapy skill sets Control (n = 11) Waitlist | Overall, % CBT: 23.1 Usual care: 18.2 P = NR
Paykel, 1999^95^ and Scott, 2000^96^ and Scott, 2003^120^ RCT 20 weeks Good | CBT (n = 80) 16 cognitive behavioral therapy sessions plus clinical management Clinical Management (n = 78) Clinical management alone – patients visited psychiatrist every 4 weeks and continued on current medication | Overall, % CBT plus clinical management: 15.4 Clinical management: 23.8 P = NR

CBT = cognitive behavioral therapy; n = number; RCT = randomized controlled trial

#### Tier 3

There were no eligible studies.

## Key Question 5 Efficacy and Harms for Selected Populations

### Overview

Studies that focused on subgroups or included a subanalysis for a special population were eligible for consideration for this KQ. Most studies were excluded because the subgroup analysis was not comparative between groups, but rather descriptive within an intervention group. Two randomized controlled trials were in specific age populations, one Tier 1 study involving rTMS compared with sham75 and one Tier 3 trial of ECT versus sham.68,127,128 Three RCTs, one Tier 1 and two Tier 2, focused on post-stroke depression, comparing rTMS to a sham intervention129,130 (Table 85).

Table 85 Number of good- and fair-quality studies by TRD tier and diagnostic mix of subpopulations presented in KQ 5

Comparison | Tier | MDD-Only | MDD and Bipolar Disorder
ECT vs. sham | Tier 3: Probable | 1 | 0
rTMS vs. sham | Tier 1: ≥ 2 treatment failures | 2 | 0
rTMS vs. sham | Tier 2: ≥ 1 treatment failure | 2 | 0

ECT, electroconvulsive therapy; rTMS = repetitive transcranial magnetic stimulation.

#### Strength of Evidence: Tier 1 (TRD)

Strength of evidence assessment was made for three outcomes: change in depressive severity, response rate, and remission rate for the two Tier 1 trials comparing rTMS versus sham (Table 86). Remission rate was not addressed in the one younger adult age group trial. Strength of evidence is low for each outcome, given that there is only one small study for each subpopulation of interest. No P value was reported for the change in depressive severity; in the one age subpopulation trial, however, there was a significant difference favoring rTMS in response rates.

Table 86 Strength of Evidence: Efficacy and other comparative clinical outcomes of rTMS versus sham -- Tier 1, MDD

Comparison | Number of Studies; Subjects | Risk of bias Design/Quality | Consistency | Directness | Precision | Results and Strength of Evidence
Change in depressive severity | 2; 54 | Low RCT Fair | Consistent | Indirect | Precise | rTMS > sham in young adult population (ages 18–37) rTMS > sham in older adults with post-stroke depression Low for age and for post-stroke depression
Response | 2; 54 | Low RCT Fair | Inconsistent | Indirect | Precise | rTMS > sham in young adult population (ages 18–37) No difference between rTMS and sham for older adults with post-stroke depression Low for age and for post-stroke depression
Remission | 1;20 | Low RCT Fair | NA | Indirect | Precise | No difference between rTMS and sham in older adults with post-stroke depression Low for post-stroke depression

RCT = randomized controlled trials; rTMS = repetitive transcranial magnetic stimulation

### Key Points

We did not identify any head-to-head comparisons for this KQ.

#### Age

Two studies provide some evidence on the efficacy of nonpharmacologic treatments in two different age groups. One, a Tier 1 study, looked at rTMS in a young adult population (ages 18 to 37); the other was a Tier 3 study in middle-aged subjects (ages 30 to 69) using ECT. A greater decrease in depressive severity and a higher response rate was seen in the trial of severely depressed younger adults undergoing 20 sessions of rTMS compared with sham. However, efficacy evidence is weaker for the 2-week trial of middle-aged adults with “severe endogenous depression,” where the depressive severity data was only shown in a figure and noted that the completers analysis found a significantly greater decrease in depressive severity with the ECT compared with sham.

#### Post-stroke Depression

We found one Tier 1 and two Tier 2 trials in older patients with vascular depression. These trials showed a greater decrease in depressive severity in those receiving rTMS treatment versus sham. Two of the three trials found statistically significant improvements, but the third trial was underpowered to detect a difference. Response and remission rates were significantly greater in the active group only for the one trial that provided 15 sessions of rTMS over 3 weeks, in comparison to 10 sessions over 2 weeks in the other trials.

### Detailed Analysis

We identified two relevant studies, both involving a comparison to a sham control (Table 87).

Table 87 Efficacy of ECT or rTMS versus sham for age subpopulations: all Tiers, MDD

Author, Year Study Design Primary Endpoint(s) Quality | Intervention and Sample Size Study Details | Population Characteristics | Response Remission Change in Depressive Symptoms | Adverse Events Quality of Life Attrition
Johnstone et al., 1980^68,127,128^ 4 weeks, completers Did not require failure in the current episode Tier 3: referred for ECT Fair | ECT (n = 35) Bilateral, 8 sessions Sham (n = 35) Treatment strategy Switch - unclear if patients taking an AD at baseline. No AD allowed during the trial mITT | Previous manic episodes: Overall: 10% Mean number of failed antidepressant trials: ECT: NR Sham: NR Baseline Depression HAM-D_17_, mean (SD) Reported in graph only | HAM-D_17_ Change, mean (SD) ECT: n= 31 Sham: n = 31 ECT vs. sham P < 0.01 (reported in graph only) HAM-D_17_ Response NR Remission NR | NR
Zheng et al., 2010 75 4 weeks Did not require failure in the current episode Tier 1 Fair | rTMS (n = 19) High frequency, 20 sessions Sham (n = 15) Treatment strategy Augment – all patients taking escitalopram 2+ weeks before trial | Baseline Depression HAM-D_17_, mean (SD) rTMS: 24.6 (2.9) Sham: 24.6 (2.8) Mean number of failed antidepressant trials: NR | HAM-D_17_ Change, mean (SD) rTMS: -11.1 Sham: -1.7 P = NR HAM-D_17_ Response, n (%) rTMS: 12 (63.2) Sham: 1 (6.7) P = 0.001 Remission NR | NR

AD = antidepressants; ECT = electroconvulsive therapy; HAM-D_17_ = 17 item Hamilton Depression Scale; mITT = modified intent-to-treat analysis; NR = not reported; P = p-value; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation

#### Age

One Tier 1 trial was conducted in a younger population, ages 18 to 37. An augmentation study, it was a 4-week trial comparing high-frequency rTMS (n = 19) to sham rTMS treatment (n = 15).75 At baseline, participants were severely depressed (HAM-D_17_ mean [SD] rTMS 24.6 [2.9] sham 24.6 [2.8]) and had been taking escitalopram for at least 2 weeks. In an ITT analysis, participants in the rTMS group had a greater decrease in depressive severity (rTMS -11.1 sham -1.7, P = NR) and a higher response rate (rTMS 63.2% sham 6.7%, P = 0.001).

A Tier 3 trial of a middle-aged population (ages 30 to 69) with “severe endogenous depression” referred for ECT compared ECT (n = 35) with sham stimulation (n = 35) for a period of 4 weeks.68 Participants in the study appear to have severe depression but these data are only reported in a graph. It is unclear what proportion of patients were on an antidepressant at study entry or had antidepressant failures in the past. During the trial, patients were not prescribed an antidepressant medication. Based on a completers analysis, the ECT group had a greater decrease in depressive severity compared to the sham group (P < 0.01).

#### Post-stroke Depression

One Tier 1 and two Tier 2 RCTs focus on patients over the age of 50 with MDD and determined to have vascular depression secondary to a vascular accident.129,130 As shown in Table 88 below, all three compare high-frequency rTMS to a sham intervention and are of fair quality. All three studies were in moderately to severely depressed study populations (mean HAM-D_17_ scores between 17 and 20 in each group) and all discontinued any antidepressants they were receiving. No significant differences were reported for headache, local pain, or anxiety. No seizures occurred in either group.

Table 88 Efficacy and other comparative harms outcomes of rTMS versus sham in post-stroke depression subpopulations: all Tiers, MDD

Author, year Study Design Primary Endpoint(s) Quality | Intervention and Sample Size Study Details | Population Characteristics | Response Remission Change in Depressive Symptoms | Adverse Events Quality of Life Attrition
Jorge et al., 2008^129^ Experiment 1 RCT, primary endpoint at 3 weeks, mITT Failure required in current episode Tier 2 Fair | rTMS (n = 15) High frequency, 10 sessions Sham (n = 15) Concurrent medications All antidepressants discontinued Strategy Switch Definitions Remission: HAM-D_17_ < 8 and did not meet criteria for major or minor depression | Subgroup Patients with stroke/cerebral vascular disease Diagnosis,% MDD: 100 Baseline Depression: HAM-D_17_ rTMS: 19.5 (5.8) Sham: 19.9 (5.4) | HAM-D_17_ Response, n (%) rTMS: 5 (33.3) Sham: 1 (6.7) P = 0.08 Remission, n (%) rTMS: 2 (13.3) Sham: 1 (6.7) P = 0.5 Change,% rTMS: -33.1 Sham: -13.6 P = 0.04 | Adverse Events Headache,% rTMS: 5 (33) Sham: 4 (27) P = NR No differences in frequency of headaches; all headaches were mild and responded to low dose analgesics Local Pain, n (%) rTMS: 1 (7) Sham: 1 (7) P = NR Local discomfort, n (%) rTMS: 4 (27) Sham: 5 (33) No difference in frequency of local discomfort P = NR Anxiety, n (%) rTMS: 2 (13) Sham: 0 (0) P = NR Seizures, n rTMS: 0 Sham: 0 P = NR
Jorge et al., 2008^129^ Experiment 2 RCT, primary endpoint at 3 weeks, mITT Failure required in current episode Tier 2 Fair | rTMS (n = 33) High frequency, 15 sessions Sham (n = 29) Concurrent medications All antidepressants discontinued Strategy Switch Definitions Remission: HAM-D_17_ <8 and did not meet criteria for major or minor depression | Subgroup Patients with stroke/cerebral vascular disease Diagnosis,% MDD: 100 Baseline Depression, n (%): HAM-D_17_ rTMS: 18.4 (3.4) Sham: 17.6 (5.6) | HAM-D_17_ Response, n (%) rTMS: 13 (39.4) Sham: 2 (6.9) P = 0.003 Remission rTMS: 9 (27.3) Sham: 1 (3.4) P = 0.01 Change,% rTMS: -42.4 Sham: -17.5 P < 0.001 | Adverse Events Headache,% rTMS: 7 (21) Sham: 3 (10) No differences between groups in frequency of headaches; all headaches were mild and responded to low dose analgesics P = NR Local Pain, n (%) rTMS: 1 (3) Sham: 0 (0) P = NR Local discomfort, n (%) rTMS: 3 (9) Sham: 1 (3) No difference in frequency of local discomfort P = NR Anxiety, n (%) rTMS: 0 (0) Sham: 0 (0) P = NR Seizures, n rTMS: 0 Sham: 0 P = NR
Jorge et al., 2004^130^ RCT, primary outcome at 3 weeks (2 weeks of txt, 1 week followup), ITT Failure in current episode not required Tier 1 Fair | rTMS (n = 10) High frequency, 10 sessions Sham (n = 10) Concurrent Medications All antidepressant medications discontinued Strategy Switch | Subgroup Patients with stroke/cerebral vascular disease Diagnosis,% MDD: 85 Minor depression: 15 Baseline Depression: HAM-D_17_ rTMS: 20.1 (6.7) Sham: 20.8 (6.0) | HAM-D_17_ Response, n (%) rTMS: 3 (30) Sham: 0 (0) P = NS Remission, n (%) rTMS: 1 (10) Sham: 0 (0) P = NS Change Score rTMS: 7.3 Sham: NR (can be calculated as 2.7) P < 0.006 Change,% rTMS: -38 Sham: -13 | Adverse Events No significant differences in frequency of adverse events between active and sham rTMS groups Neither group reported seizures or propagation of cortical excitability toipsilateral motor cortex

HAM-D_17_ = 17-item Hamilton Depression Scale; ITT = intent-to-treat analysis; MDD = major depressive disorder; mITT = modified intent-to-treat analysis; NR = not reported; NS = not significant; P = p-value; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; txt = treatment

Two experiments are presented in one article where all patients had at least one antidepressant medication failure.129 The active intervention in the first study applied 10 sessions of rTMS to 15 patients (15 in the sham group). In a modified ITT analysis after 3 weeks of treatment, the rTMS group had a greater percentage decrease in HAM-D_17_ (33.1% versus 13.6%, P = 0.04) and tended to have a greater response rate, but the difference was not significant. Remission rates in each group were low, but also not significant. The second study increased the number of sessions to 15 and showed a greater decrease in depressive severity in the rTMS group with significantly improved response and remission rates after 3 weeks of treatment. In this experiment, 33 patients received 15 sessions (29 patients in sham group) and resulted in a greater percentage decrease in HAM-D_17_ (42.4% versus 17.5%, P = 0.001), response rate (39.4% versus 6.9%, P = 0.003) and remission (27.3% versus 3.4%, P = 0.01) in comparison to the sham intervention group.

In the third trial of 20 patients who had two antidepressant trial failures, 10 patients were treated with rTMS over 10 sessions and 10 received the sham treatment.130 Those in the rTMS group showed a greater decrease in depressive severity, though the study did not have the power to adequately compare response and remission rates.130 Mean baseline depressive severity was moderate, with both groups averaging between 20 and 21 points on the HAM-D_17_. Antidepressants were tapered to discontinuation prior to enrollment, so patients were switched to rTMS or control. An ITT analysis at 3 weeks found that outcomes favored the rTMS group. Compared to control, rTMS produced a greater decrease in depressive severity (-7.3 versus -2.7, P < 0.006) and a greater likelihood of both response (3 out of 10 versus 0 out of 10) and remission (1 of 10 versus 0 of 10).

## Key Question 6 Health-Related Outcomes—Overview

Understanding the burden of affective disorders on the quality of life of patients is an important component to establishing the overall effectiveness of treatment for these disorders. However, quality of life is rarely assessed in this body of literature. Previous ECT studies have associated ECT with a post-treatment quality-of-life improvement that can be maintained from 1 month to 1 year.61 Very little quality-of-life data following rTMS, VNS, behavioral, or other nonpharmacologic treatments are available.

Numerous psychometric measures exist to assess an individual's level of functioning and execution of daily living activities, which are both health domains that are related to quality of life. The Global Assessment of Functioning (GAF) and the Longitudinal Interval Follow-up Evaluation Range of Impaired Functioning Tool (LIFE-RIFT) are scales used to determine patients' ability to function in daily life.131,132 The Medical Outcomes Study 36 Item Short Form (MOS SF-36 or SF-36) is an internationally recognized generic health survey instrument comprised of 36 items in eight independent health domains used to survey the health status of an individual.133 The Quality of Life Enjoyment and Satisfaction Questionnaire (Q-LES-Q) is a 16-item questionnaire that uses a self-report measure to obtain the degree of enjoyment and satisfaction of various areas of daily functioning.134,135 Finally, the Social Adjustment Scale-Self-Report (SAS-SR) work subscale taps a subset of daily activities that may indirectly reflect patients' quality of life.136

The following KQ focuses on the comparative benefit of patient-reported health-related outcomes using quality of life measures with TRD (MDD/bipolar and MDD-only). There were no head-to-head (direct) comparisons identified. Four indirect comparison studies were available and assessed general health status and mental and physical functioning. Two studies compared rTMS versus sham, one study compared VNS versus sham, and one study compared CBT versus control.

For TRD populations (Tier 1), we identified two studies, both in MDD/bipolar mix samples (Table 89), one comparing rTMS versus sham80 and one comparing VNS versus sham.98 Both studies suggested greater benefit for rTMS over the control. An additional study compared MDD patients comparing ECT versus ECT plus rTMS.64

Table 89 Number of good- and fair-quality studies by TRD tier and diagnostic mix for KQ 6

Comparison | Tier | MDD-only | MDD and Bipolar Disorder
ECT vs. rTMS | Tier 2: ≥ 1 treatment failure | 1 | 0
rTMS vs. Sham | Tier 1: ≥ 2 treatment failures | 0 | 1
rTMS vs. Sham | Tier 2: ≥ 1 treatment failure | 0 | 1
VNS vs. Sham | Tier 1: ≥ 2 treatment failures | 0 | 1
CBT vs. Control | Tier 2: ≥ 1 treatment failure | 2 | 0

CBT = cognitive behavioral therapy; ECT = electroconvulsive therapy; rTMS = repetetive transcranial magnetic simulation; VNS = vagus nerve stimulation; vs. = versus

Considering additional tiers added two Tier 2 studies of MDD-only populations comparing CBT versus control group93,94 that showed no difference in outcomes (Table 89). Additionally, a study that compared rTMS to sham is in Tier 2 and suggests an increase in quality of life in the active group using the SF-36 and the Q-LES-Q.87,115,116,119,124,125 A tier 2 study conducted in 40 patients comparing ECT to rTMS illustrated improvements in quality of life using the GAF.118

### Strength of Evidence: Tier 1 (TRD)

One study directly compared the effect of nonpharmacologic treatment on patient-reported health-related outcomes. The study shows no difference in quality of life that compared ECT to ECT plus rTMS.64 No evidence directly compared the effect of nonpharmacologic treatment on patient-reported health-related outcomes. Three studies provided indirect evidence. Neither of these two Tier 1 studies assessed quality of life for a nonpharmacologic intervention versus control, instead assessing general health status and mental and physical functioning, and related health domains, for a nonpharmacologic treatment versus sham comparison. One study provided insufficient strength of evidence to assess whether there was a greater improvement in the ability to function following treatment with rTMS compared to sham, as results were mixed (Table 90).80 Results were in the same direction favoring rTMS, but one of the active arms (low-right rTMS) produced statistically greater improvement than sham, while the second active arm (high-left rTMS) produced greater improvement that did not reach statistical significance. The other study provided low strength of evidence that health status did not differ significantly following treatment with VNS or sham.98

Table 90 Strength of Evidence: Health-related outcome measures – Tier 1

Comparison | Number of studies; subjects | Risk of bias Design Quality | Consistency | Directness | Precision | Results and Strength of Evidence
ECT vs. ECT + rTMS | 1, 22 | Medium 1 RCT 1 Fair | Unknown | Indirect | Imprecise | No difference between groups in improvements to daily functioning Low
rTMS vs. sham | 1; 60 | Medium 1 RCT 1 Fair | Unknown | Indirect | Imprecise | High-left rTMS produces greater improvement in health status and daily functioning than sham (P = 0.09) Low rTMS produces greater improvement in health status and daily functioning than sham (P = 0.03) Low
VNS vs. sham | 1; 214 | Medium 1 RCT 1 Fair | Unknown | Indirect | Imprecise | No difference between VNS vs. sham in daily functioning Low

ECT = electroconvulsive therapy; NA = not applicable; P = p-value; RCT = randomized controlled trial; rTMS = transcranial magnetic stimulation; VNS = vagus nerve stimulation; vs. = versus

## Key Question 6 Health-Related Outcomes-Key Points

One study directly compared the effect of nonpharmacologic treatment on patient-reported health-related outcomes (ECT to ECT plus rTMS study).64

We identified five relevant studies that compared outcomes related to quality of life for patients who underwent rTMS or VNS versus sham, or CBT compared to a control group. Three studies87,93,94,115,116,119,124,125 involved patients with MDD-only, and the other two studies80,98 involved patients with MDD and/or bipolar disorder. The studies were funded by the United States federal government, hospitals, and universities. The active treatment duration across studies ranged from 2 to 16 weeks.

Overall, the study samples were relatively small; two of the four studies had study samples of 50 or fewer patients, but one had a study sample of 491. All studies were RCTs and were rated as fair quality. One study found statistically significant differences in GAF between one active arm and sham, but not between the other active arm and sham.80 Additionally, two studies reported significant changes (P < 0.05) in the SAS-SR work subscale and the SF-36 Mental Component Score and the Q-LES-Q Total Score, respectively.87,93,115,116,119,124,125

## Key Question 6 Health-Related Outcomes—Detailed Analysis

### Electroconvulsive Therapy Versus Repetitive Transcranial Magnetic Stimulation

#### Tier 1

No Tier 1 data were available for either the MDD-only or MDD/bipolar populations.

#### Tier 2. Patients With one or More Treatment Failures

##### MDD-Only

One study compared ECT versus rTMS in 40 patients (Table 91).59 The study used the GAF to measure changes in functioning in the patients. Though both groups showed improvement from baseline, there were no between group differences in the measure.

Table 91 Quality of life of ECT versus rTMS: Tier 2, MDD

Author, Year Study Design Endpoint Episode Failure Quality | Intervention and Sample Size Study Details | Results
Grunhaus et al., 2003^59^ RCT Did not specify failure in the current episode 4 weeks Fair | ECT (n = 20) 35% bilateral, mean sessions 10.25 (SD 3.1) rTMS (n = 20) High frequency, 20 sessions (4 weeks) | Global Assessment of Functioning (GAF) Baseline score, mean (SD) ECT: 39.8 (9.3) rTMS: 48.9 (10.8) Endpoint score, mean (SD) ECT: 60.6 (13.5) rTMS: 62.5 (18.8) Group by time interaction, P = NS

ECT = electroconvulsive therapy; NS = not significant; P = p-value; RCT = randomized controlled trial; rTMS = transcranial magnetic stimulation; SD = standard error

#### Tier 3

No Tier 3 data were available for either the MDD-only or MDD/bipolar populations.

### Electroconvulsive Therapy Versus Electroconvulsive Therapy Plus Repetitive Transcranial Magnetic Stimulation

#### Tier 1: Patients With two or More Treatment Failures

##### MDD-Only

One study compared ECT and an ECT plus rTMS using the GAF to assess quality of life (Table 92).64 The intervention groups did not differ significantly on the final score.

Table 92 Quality of life of ECT versus ECT plus rTMS: Tier 1, MDD

Author, Year Study Design Endpoint Episode Failure Quality | Intervention and Sample Size Study Details | Results
Pridmore et al., 2000^64^ RCT 2 to 4 weeks Did not specify failure in the current episode Fair | ECT (n = 11) 100% unilateral, 6 sessions ECT plus rTMS (n = 11) ECT: 100% unilateral (day 1), plus high-frequency rTMS: (days 2-5) Repeated in week 2; 8 sessions | Global Assessment of Functioning Baseline score, median ECT: 41 ECT plus rTMS: 41 Endpoint (at 2 weeks) score, median (SD) ECT: 70 ECT plus rTMS: 65 Comparison of median difference between groups, P = NS

ECT = electroconvulsive therapy; NS = not significant; P = p-value; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation

##### MDD/Bipolar

No data available.

#### Tier 2

No Tier 2 data were available for either the MDD-only or MDD/bipolar populations.

#### Tier 3

No Tier 3 data were available for either the MDD-only or MDD/bipolar populations.

### Repetitive Transcranial Magnetic Stimulation Versus Sham

#### Tier 1: Patients With two or More Treatment Failures

##### MDD-Only

There were no eligible studies.

##### MDD/Bipolar

One study compared rTMS treatment (two versions—LFR-rTMS and HFL-rTMS) to a sham procedure and found no significant differences between the active rTMS groups compared with the sham group in the GAF mean score change (Table 93).80 However, they found a statistically significant difference in the GAF mean score change between the LFR-rTMS versus sham groups (P = 0.03), though the difference is not clinically significant as all groups remained in the 41–50 point range, which is rated as serious symptoms (e.g., suicidal ideation, severe obsessional rituals, frequent shoplifting) or any serious impairment in social, occupational, or school functioning (e.g., no friends, unable to keep a job).137

Table 93 Quality of life of rTMS versus sham: Tier 1, MDD and ≤ 20 percent bipolar disorder

Author, Year Study Design Endpoint Episode Failure Quality | Intervention and Sample Size Study Details | Results
Fitzgerald et al., 2003^80^ 2 weeks, all reported patients included Did not require failure in the current episode Fair | High-rTMS (n = 20) High frequency, 10 sessions Low-rTMS (n = 20) Low frequency, 10 sessions Sham (n = 20) | Global Assessment of Functioning Baseline score, mean (SD) High rTMS: 43.0 (6.8) Low rTMS: 43.5 (9.9) Sham: 42.7 (7.1) Endpoint score, mean (SD) At week 2 High rTMS: 45.2 (7.1) Low rTMS: 46.3 (8.5) Sham: 42.5 (6.8) Change, mean At week 2 High rTMS: 2.2 Low rTMS: 1.4 Sham: 0.2 High rTMS vs. sham: P = 0.09 Low rTMS vs. sham: P = 0.03

n = number; P = p-value; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation; VNS = vagus nerve stimulation; vs = versus

#### Tier 2: Patients With one or More Treatment Failures

##### MDD-Only

One study compared rTMS to sham procedure and found significant differences between the two groups in both the SF-36 mental component score (P = 0.032) and the Q-LES-Q total score (P = 0.035) (Table 94).87,115,116,119,125,138These changes are small and their clinical significance is unclear.

Table 94 Quality of life of rTMS versus sham: Tier 2, MDD and ≤ 20 percent bipolar disorder

Author, Year Study Design Endpoint Episode Failure Quality | Intervention and Sample Size Study Details | Results
O'Reardon et al., 2007,^87^ Janicak et al,2007,^115^ and Solvason et al., 2007^116^ RCT 6 weeks, all reported patients included Required to have failed at least one in this or most recent episode or four failed attempts in lifetime. Fair | rTMS (n=155) High frequency, up to 30 sessions Sham (n=146) | Medical Outcomes Study Short Form-36 Mental Component Score, mean (SD) Baseline score rTMS: 20.4 (8.05) Sham: 20.4 (7.76) Change at week 6 rTMS: 5.7 (12.65) Sham: 2.9 (10.6) P = 0.032 Physical Component Score, mean (SD) Baseline score rTMS: 50.5 (11.01) Sham: 48.8 (10.35) Change at week 6 rTMS: 0.1 (7.49) Sham: -0.2 (7.23) P = 0.682 Quality of Life, Enjoyment and Satisfaction Questionnaire –Short Form Baseline score, mean (SD) rTMS: 37.8 (8.23) Sham: 36.5 (7.87) Endpoint score, mean (SD) At week 6 rTMS: 42.2 (12.28) Sham: 39.0 (10.15) Change, mean At week 6 rTMS: 2.0 (9.24) Sham: 1.3 (9.85) P = 0.035

n = number; P = p-value; RCT = randomized controlled trial; rTMS = repetitive transcranial magnetic stimulation; SD = standard deviation

##### MDD/Bipolar

There were no eligible studies.

#### Tier 3

No Tier 3 data were available for either the MDD-only or MDD/bipolar populations.

### Vagus Nerve Stimulation Versus Sham

#### Tier 1. Patients With two or More Treatment Failures

##### MDD-Only

There were no eligible studies.

##### MDD/Bipolar

One study compared VNS and a sham procedure using the MOS SF-36 to assess quality of life (Table 95).98 The intervention and control groups did not differ significantly on either the mental or physical components of the MOS SF-36 instrument.

Table 95 Quality of life of VNS versus sham: Tier 1, MDD and ≤ 20 percent bipolar disorder

Author, Year Endpoint Episode Failure Quality | Intervention and Sample Size Study Details | Results
Rush et al., 2005^98^ 10 weeks Two to six failures in current episode. Fair | VNS (n = 112) 10 weeks of VNS therapy with continued medications Sham (n = 110) Sham: device implanted but not turned on | Medical Outcomes Study Short Form-36 Analyzed, n VNS: 107 Sham:107 Physical component, change mean (SD) VNS: -0.9 (8.3) Sham: -1.6 (8.4) P = 0.480 Mental component, change mean (SD) VNS: 5.0 (11.6) Sham: 4.0 (10.2) P = 0.406

n = number; P = p-value; SD = standard deviation; VNS = vagus nerve stimulation

#### Tier 3

No Tier 3 data were available for either the MDD-only or MDD/bipolar populations.

### Cognitive Behavioral Therapy Versus Control

#### Tier 1

No Tier 1 data were available for either the MDD-only or MDD/bipolar populations.

#### Tier 2. Patients With one or More Treatment Failures

##### MDD-Only

The Harley et al. study, rated fair quality, compared patients receiving psychotherapy such as CBT or IPT with a control group using the LIFE-RIFT instrument (Table 96).93 They found no significant differences between the intervention and control groups. They also used the SAS-SR work subscale as a measure of quality of life, reporting a significant difference (P < 0.05) between the psychotherapy group compared with the control group.

Table 96 Quality of life of CBT versus control: Tier 2, MDD

Author, Year Endpoint Episode Failure Quality | Intervention and Sample Size Study Details | Results
Harley et al., 2008^93^ 16 weeks, all reported patients included Did not require failure in the current episode Fair | CBT [DBT] (n = 10) 16 weekly sessions of dialectical behavior therapy skills training Control (n = 9) Waitlist | Lifework-The Range of Impaired Functioning Tool Change, mean (SD) CBT: -1.3 Control: -0.33 P = NS Social Adjustment Scale-Self-Report (SAS-Self Report) work subscale Baseline score, mean (SD) CBT/DBT: 82.50 (21.21) Control: 69.22 (17.95) Endpoint score, mean (SD) CBT/DBT: 65.70 (19.27) Control: 69.56 (17.66) Change, mean CBT/DBT: -16.80 Control: 0.34 P < 0.05
Kocsis et al., 2009^94^ RCT 12 weeks Fair | CBASP (n=200) Cognitive behavioral analysis system of psychotherapy plus medication; 16-20 sessions BSP (n=195) Brief Supportive Psychotherapy; usual medication; 16-20 sessions No psychoterapy (n=96) Medication only | Life-Rift Sore Baseline score, mean (SD) CBASP: 12.69 (2.96) BSP: 12.71 (3.14) No psychotherapy: 12.64 (3.01) Endpoint score, mean (SD) CBASP: 10.24 (3.25) BSP: 10.73 (3.46) No psychotherapy: 10.96 (3.63) Difference, mean CBASP: 2.45 BSP: 1.98 No psychotherapy: 1.68 No difference between comparisons

BSP = brief supportive psychotherapy; CBASP = cognitive behavioral analysis system of psychotherapy; CBT = cognitive behavioral therapy; DBT = dialectical behavior therapy; Lifework-RIFT = Lifework-The Range of Impaired Functioning Tool; SD = standard deviation

A larger study in 491 participants compared three interventions, two forms of psychotherapy used in conjunction with medication and just medication with no psychotherapy.94 It measured quality of life using LIFE-RIFT and found no differences between the interventions.

##### MDD/Bipolar

There were no eligible studies.

#### Tier 3

No Tier 3 data were available for either the MDD-only or MDD/bipolar populations.