# References

1 Kessler RC, Berglund P, Demler O, et al. The epidemiology of major depressive disorder: results from the National Comorbidity Survey Replication (NCS-R). JAMA. Jun. 18. 2003;289(23):3095-3105. [pmid: 12813115].
2 Wang PS, Lane M, Olfson M, et al. Twelve-month use of mental health services in the United States: results from the National Comorbidity Survey Replication. Arch Gen Psychiatry. Jun. 2005;62(6):629-40. [pmid: 15939840].
3 American Psychiatric Association. Practice guideline for the treatment of patients with major depressive disorder (revision). American Journal of Psychiatry. Apr. 2000;157(4 Suppl):1-42. [pmid: 10767867].
4 Qaseem A, Snow V, Denberg TD, et al. Using second-generation antidepressants to treat depressive disorders: a clinical practice guideline from the American College of Physicians, Ann Intern Med. Nov. 18. 2008;149(10):725-33. [pmid: 19017591].
5 Kupfer DJ. Long-term treatment of depression. J Clin Psychiatry. May. Suppl. 1991;52:28-34. [pmid: 1903134].
6 Trivedi MH, Rush AJ, Wisniewski SR, et al. Evaluation of outcomes with citalopram for depression using measurement-based care in STAR*D: implications for clinical practice. Am J Psychiatry. Jan. 2006;163(1):28-40. [pmid: 16390886].
7 Thase ME, Rush AJ. When at first you don't succeed: sequential strategies for antidepressant nonresponders. J Clin Psychiatry. 13. 1997;58:23-9. [pmid: 9402916].
8 Rush AJ, Trivedi MH, Wisniewski SR, et al. Acute and longer-term outcomes in depressed outpatients requiring one or several treatment steps: A STAR*D report. American Journal of Psychiatry. 2006;163(11):1905-17. PMID:. [pmid: 17074942].
9 Berlim MT, Fleck MP, Turecki G. Current trends in the assessment and somatic treatment of resistant/refractory major depression: an overview. Ann Med. 2008;40(2):149-59. [pmid: 18293145].
10 Thase ME. New approaches to managing difficult-to-treat depressions. The J Clin Psychiatry. 2003:643-4.
11 Russell JM, Hawkins K, Ozminkowski RJ, et al. The cost consequences of treatment-resistant depression. J Clin Psychiatry. Mar. 2004;65(3):341-7. [pmid: 15096073].
12 Crown WH, Finkelstein S, Berndt ER, et al. The impact of treatment-resistant depression on health care utilization and costs. J Clin Psychiatry. Nov. 2002;63(11):963-71. [pmid: 12444808].
13 Greenberg P, Corey-Lisle PK, Birnbaum H, et al. Economic implications of treatment-resistant depression among employees. Pharmacoeconomics. 2004;22(6):363-73. [pmid: 15099122].
14 Gartlehner G, Gaynes BN, Hansen RA, et al. Comparative benefits and harms of second-generation antidepressants: background paper for the American College of Physicians. Ann Intern Med. Nov. 18. 2008;149(10):734-50. [pmid: 19017592].
15 Tharyan P. The Cochrane Schizophrenia Group: preparing, maintaining and disseminating the evidence for interventions used for people with schizophrenia. Int Rev Psychiatry. Apr. 2005;17(2):115-21. [pmid: 16194781].
16 Greenhalgh J, Knight C, Hind D, et al. Clinical and cost-effectiveness of electroconvulsive therapy for depressive illness, schizophrenia, catatonia and mania: systematic reviews and economic modelling studies. Health Technol Assess. Mar. 2005;9(9):1-156. iii. iv. [pmid: 15774232].
17 Lisanby SH. Electroconvulsive therapy for depression. N Engl J Med. Nov. 8. 2007;357(19):1939-45. [pmid: 17989386].
18 Fitzgerald PB, Benitez J, de Castella A, et al. A randomized, controlled trial of sequential bilateral repetitive transcranial magnetic stimulation for treatment-resistant depression. Am J Psychiatry. Jan. 2006;163(1):88-94. [pmid: 16390894].
19 Feldman G. Cognitive and behavioral therapies for depression: overview, new directions, and practical recommendations for dissemination. Psychiatr Clin North Am. Mar. 2007;30(1):39-50. [pmid: 17362802].
20 Schramm E, van Calker D, Dykierek P, et al. An intensive treatment program of interpersonal psychotherapy plus pharmacotherapy for depressed inpatients: acute and long-term results. Am J Psychiatry. May. 2007;164(5):768-77. [pmid: 17475736].
21 George MS, Belmaker RH, editors. Transcranial magnetic stimulation in clinical psychiatry. Arlington, VA. American Psychiatric Publishing. 2007.
22 Shapira B, Tubi N, Lerer B. Balancing speed of response to ECT in major depression and adverse cognitive effects: role of treatment schedule. J Ect. Jun. 2000;16(2):97-109. [pmid: 10868320].
23 Rossi S, Hallett M, Rossini PM, et al. Safety, ethical considerations, and application guidelines for the use of transcranial magnetic stimulation in clinical practice and research. Clin Neurophysiol. Dec. 2009;120(12):2008-39. [pmid: 19833552].
24 Daban C, Martinez-Aran A, Cruz N, et al. Safety and efficacy of Vagus Nerve Stimulation in treatment-resistant depression. A systematic review. J Affect Disord. Sep. 2008;110(1-2):1-15. [pmid: 18374988].
25 Neuronetics. NeuroStar TMS System™ User Manual. 2006.
26 Lisanby SH, Pallanti S, Schlaepfer TE. FDA considers classification of ECT. CNS Spectrums. 2009;14(12):668-70. PMID:. [pmid: 20394174].
27 Centers for Medicare & Medicaid Services. Update-Inpatient Psychiatric Facilities Prospective Payment System (IPF PPS). Rate Year 2009, Publication # 100-04. 2008. June. 27.
28 Patel M, Patel S, Hardy DW, et al. Should electroconvulsive therapy be an early consideration for suicidal patients. J ECT. Jun. 2006;22(2):113-5. [pmid: 16801826].
29 Tew JD Jr, Mulsant BH, Haskett RF, et al. Acute efficacy of ECT in the treatment of major depression in the old-old. Am J Psychiatry. Dec. 1999;156(12):1865-70. [pmid: 10588398].
30 Van Der Wurff FB, Stek ML, Hoogendijk WJ, et al. The efficacy and safety of ECT in depressed older adults: a literature review (Brief record). International Journal of Geriatric Psychiatry. 2003;(10):894-904. [pmid: 14533122].
31 Walter G, Martin J, Kirkby K, et al. Transcranial magnetic stimulation: experience, knowledge and attitudes of recipients. Aust N Z J Psychiatry. Feb. 2001;35(1):58-61. [pmid: 11270457].
32 Simpson KN, Welch MJ, Kozel FA, et al. Cost-effectiveness of transcranial magnetic stimulation in the treatment of major depression: a health economics analysis. Adv Ther. Mar. 2009;26(3):346-68. [pmid: 19330495].
33 Marangell LB, Martinez M, Jurdi RA, et al. Neurostimulation therapies in depression: a review of new modalities. Acta Psychiatr Scand. Sep. 2007;116(3):174-81. [pmid: 17655558].
34 Melkerson MN. Special Premarket 510(k) Notification for NeuroStar TMS Therapy System for Major Depressive Disorder. 2008. Available at: http://www.accessdata.fda.gov/cdrh_docs/pdf8/K083538.pdf.
35 Belmaker B, Fitzgerald P, George MS, et al. Managing the risks of repetitive transcranial stimulation. CNS Spectrums. 2003;8(7). PMID:.
36 Shuchman M. Approving the vagus-nerve stimulator for depression. N Engl J Med. 2007;356(16):1604-7. PMID:. [pmid: 17442903].
37 Lulic D, Ahmadian A, Baaj AA, et al. Vagus nerve stimulation. Neurosurg Focus. Sep. 2009;27(3):E5. [pmid: 19722820].
38 Federal Drug Administration. Summary of Safety and Effectiveness Data: Stimulator, Vagus Nerve. 20051-23.
39 Cohen LJ, Allen JC Jr. Estimating the potential savings with vagus nerve stimulation for treatment-resistant depression: a payer perspective. Curr Med Res Opin. Aug. 2008;24(8):2203-17. [pmid: 18786301].
40 Rush AJ, Siefert SE. Clinical issues in considering vagus nerve stimulation for treatment-resistant depression. Exp Neurol. Sep. 2009;219(1):36-43. [pmid: 19397908].
41 Rush AJ, Sackeim HA, Marangell LB, et al. Effects of 12 months of vagus nerve stimulation in treatment-resistant depression: a naturalistic study. Biol Psychiatry. Sep. 1. 2005;58(5):355-63. [pmid: 16139581].
42 George MS, Rush AJ, Marangell LB, et al. A one-year comparison of vagus nerve stimulation with treatment as usual for treatment-resistant depression. Biol Psychiatry. Sep. 1. 2005;58(5):364-73. [pmid: 16139582].
43 Luty SE, Carter JD, McKenzie JM, et al. Randomised controlled trial of interpersonal psychotherapy and cognitive-behavioural therapy for depression. Br J Psychiatry. Jun. 2007;190:496-502. [pmid: 17541109].
44 Bortolotti B, Menchetti M, Bellini F, et al. Psychological interventions for major depression in primary care: a meta-analytic review of randomized controlled trials. Gen Hosp Psychiatry. Jul-Aug. 2008;30(4):293-302. [pmid: 18585531].
45 Butler AC, Chapman JE, Forman EM, et al. The empirical status of cognitive-behavioral therapy: a review of meta-analyses. Clin Psychol Rev. Jan. 2006;26(1):17-31. [pmid: 16199119].
46 DeRubeis RJ, Hollon SD, Amsterdam JD, et al. Cognitive therapy vs medications in the treatment of moderate to severe depression. Arch Gen Psychiatry. Apr. 2005;62(4):409-16. [pmid: 15809408].
47 Shelton RC, Osuntokun O, Heinloth AN, et al. Therapeutic options for treatment-resistant depression. CNS Drugs. Feb. 1. 2010;24(2):131-61. [pmid: 20088620].
48 Berlim MT, Turecki G. What is the meaning of treatment resistant/refractory major depression (TRD)? A systematic review of current randomized trials. Eur Neuropsychopharmacol. Nov. 2007;17(11):696-707. [pmid: 17521891].
49 Berlim MT, Turecki G. Definition, assessment, and staging of treatment-resistant refractory major depression: a review of current concepts and methods. Can J Psychiatry. Jan. 2007;52(1):46-54. [pmid: 17444078].
50 Fornaro M, Giosue P. Current nosology of treatment resistant depression: a controversy resistant to revision. Clin Pract Epidemiol Ment Health. 2010:620-4. [pmid: 20563286].
51 Malhi GS, Parker GB, Crawford J, et al. Treatment-resistant depression: resistant to definition. Acta Psychiatr Scand. Oct. 2005;112(4):302-9. [pmid: 16156838].
52 Goldberg DP, Andrews G, Hobbs MJ. Where should bipolar disorder appear in the meta-structure?. Psychological Medicine. 2009;39(12):2071-81. PMID:. [pmid: 19796430].
53 Lisanby SH, Gutman D, Luber B, et al. Sham TMS: intracerebral measurement of the induced electrical field and the induction of motor-evoked potentials. Biol Psychiatry. Mar. 1. 2001;49(5):460-3. [pmid: 11274658].
54 Loo CK, Taylor JL, Gandevia SC, et al. Transcranial magnetic stimulation (TMS) in controlled treatment studies: are some “sham” forms active?. Biol Psychiatry. 2004;47(4):325-31. [pmid: 10686267].
55 Inventory of Depressive Symptomatology (IDS) and Quick Inventory of Depressive Symptomatology (QIDS). University of Pittsburgh Epidemiology Data Center. 2010. Available at: http://www.ids-qids.org/index2.html.
56 Owens DK, Lohr KN, Atkins D, et al. Grading the strength of a body of evidence when comparing medical interventions--Agency for Healthcare Research and Quality and the Effective Health Care Program, Journal of Clinical Epidemiology. 2010;63(5):513-23. PMID:.
57 Agency for Healthcare Research and Quality. Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews. Version 1.0 [Draft posted Oct 2007]. Rockville, MD. Available at: http://effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf.
58 Rosa MA, Gattaz WF, Pascual-Leone A, et al. Comparison of repetitive transcranial magnetic stimulation and electroconvulsive therapy in unipolar non-psychotic refractory depression: a randomized, single-blind study. Int J Neuropsychopharmacol. Dec. 2006;9(6):667-76. [pmid: 16923322].
59 Grunhaus L, Schreiber S, Dolberg OT, et al. A randomized controlled comparison of electroconvulsive therapy and repetitive transcranial magnetic stimulation in severe and resistant nonpsychotic major depression. Biol Psychiatry. Feb. 15. 2003;53(4):324-31. [pmid: 12586451].
60 Hansen PE, Ravnkilde B, Videbech P, et al. Low-frequency repetitive transcranial magnetic stimulation inferior to electroconvulsive therapy in treating depression. J ECT. 2010. Mar. 25. [pmid: 20351570].
61 McLoughlin DM, Mogg A, Eranti S, et al. The clinical effectiveness and cost of repetitive transcranial magnetic stimulation versus electroconvulsive therapy in severe depression: a multicentre pragmatic randomised controlled trial and economic analysis. Health Technol Assess. Jul. 2007;11(24):1-54. [pmid: 17580003].
62 Eranti S, Mogg A, Pluck G, et al. A randomized, controlled trial with 6-month follow-up of repetitive transcranial magnetic stimulation and electroconvulsive therapy for severe depression. Am J Psychiatry. Jan. 2007;164(1):73-81. [pmid: 17202547].
63 Knapp M, Romeo R, Mogg A, et al. Cost-effectiveness of transcranial magnetic stimulation vs electroconvulsive therapy for severe depression: A multi-centre randomised controlled trial. Journal of Affective Disorders. Aug. 2008. 2008;109(3):273-85. [pmid: 18262655].
64 Pridmore S. Substitution of rapid transcranial magnetic stimulation treatments for electroconvulsive therapy treatments in a course of electroconvulsive therapy. Depress Anxiety. 2000;12(3):118-23. [pmid: 11126185].
65 Chistyakov AV, Kaplan B, Rubichek O, et al. Effect of electroconvulsive therapy on cortical excitability in patients with major depression: a transcranial magnetic stimulation study. Clin Neurophysiol. Feb. 2005;116(2):386-92. [pmid: 15661116].
66 Folkerts HW, Michael N, Tölle R, et al. Electroconvulsive therapy vs. paroxetine in treatment-resistant depression -- a randomized study. Acta Psychiatr Scand. Nov. 1997;96(5):334-42. [pmid: 9395150].
67 West ED. Electric convulsion therapy in depression: a double-blind controlled trial. Br Med J (Clin Res Ed). 1981;282(6261):355-7. [pmid: 6780021].
68 Johnstone EC, Deakin JF, Lawler P, et al. The Northwick Park electroconvulsive therapy trial. Lancet. 1980;2(8208-8209):1317-20. [pmid: 6109147].
69 Boutros NN, Gueorguieva R, Hoffman RE, et al. Lack of a therapeutic effect of a 2-week sub-threshold transcranial magnetic stimulation course for treatment-resistant depression. Psychiatry Research. Dec. 2002;113(3):245-54. [pmid: 12559481].
70 Garcia-Toro M, Mayol A, Arnillas H, et al. Modest adjunctive benefit with transcranial magnetic stimulation in medication-resistant depression. Journal of Affective Disorders. May. 2001;64(2):271-5. [pmid: 11313095].
71 Garcia-Toro M, Salva J, Daumal J, et al. High (20-Hz) and low (1-Hz) frequency transcranial magnetic stimulation as adjuvant treatment in medication-resistant depression. Psychiatry Res. Jan. 30. 2006;146(1):53-7. [pmid: 16356697].
72 Kauffmann CD, Cheema MA, Miller BE. Slow right prefrontal transcranial magnetic stimulation as a treatment for medication-resistant depression: a double-blind, placebo-controlled study. Depression and Anxiety. 2004;19(1):59-62. [pmid: 14978787].
73 Padberg F, Zwanzger P, Thoma H, et al. Repetitive transcranial magnetic stimulation (rTMS) in pharmacotherapy-refractory major depression: comparative study of fast, slow and sham rTMS. Psychiatry Res. 1999;88(3):163-71. [pmid: 10622338].
74 Pallanti S, Bernardi S, Di Rollo A, et al. Unilateral low frequency versus sequential bilateral repetitive transcranial magnetic stimulation: is simpler better for treatment of resistant depression?. Neuroscience. 2010;167(2):323-8. [pmid: 20144692].
75 Zheng H, Zhang L, Li L, et al. High-frequency rTMS treatment increases left prefrontal myo-inositol in young patients with treatment-resistant depression, Progress in Neuro-Psychopharmacology & Biological Psychiatry. 2010;34(7):1189-95. First Author & Affiliation: Zheng, Huirong.
76 Holtzheimer PE 3rd, Russo J, Claypoole KH, et al. Shorter duration of depressive episode may predict response to repetitive transcranial magnetic stimulation. Depress Anxiety. 2004;19(1):24-30. [pmid: 14978782].
77 Avery DH, Holtzheimer PE 3rd, Fawaz W, et al. A controlled study of repetitive transcranial magnetic stimulation in medication-resistant major depression. Biol Psychiatry. Jan. 15. 2006;59(2):187-94. [pmid: 16139808].
78 Pascual-Leone A, Rubio B, Pallardo F, et al. Rapid-rate transcranial magnetic stimulation of left dorsolateral prefrontal cortex in drug-resistant depression. Lancet. Jul. 27. 1996;348(9022):233-7. [pmid: 8684201].
79 Bocchio-Chiavetto L, Miniussi C, Zanardini R, et al. 5-HTTLPR and BDNF Val66Met polymorphisms and response to rTMS treatment in drug resistant depression. Neurosci Lett. May. 30. 2008;437(2):130-4. [pmid: 18450378].
80 Fitzgerald PB, Brown TL, Marston NA, et al. Transcranial magnetic stimulation in the treatment of depression: a double-blind, placebo-controlled trial. Arch Gen Psychiatry. Oct. 2003;60(10):1002-8. [pmid: 14557145].
81 Su TP, Huang CC, Wei IH. Add-On rTMS for medication-resistant depression: a randomized, double-blind, sham-controlled trial in Chinese patients. Journal of Clinical Psychiatry. Jul. 2005. 2005;66(7):930-7. [pmid: 16013911].
82 Triggs WJ, Ricciuti N, Ward HE, et al. Right and left dorsolateral pre-frontal rTMS treatment of refractory depression: a randomized, sham-controlled trial. Psychiatry Res. 2010;178(3):467-74. [pmid: 20643486].
83 George MS, Lisanby SH, Avery D, et al. Daily left prefrontal transcranial magnetic stimulation therapy for major depressive disorder: a sham-controlled randomized trial. Arch Gen Psychiatry. May. 2010;67(5):507-16. [pmid: 20439832].
84 Manes F, Jorge R, Morcuende M, et al. A controlled study of repetitive transcranial magnetic stimulation as a treatment of depression in the elderly. International Psychogeriatrics. Jun. 2001. 2001;13(2):225-31. [pmid: 11495396].
85 Moser DJ, Jorge RE, Manes F, et al. Improved executive functioning following repetitive transcranial magnetic stimulation. Neurology. 2002;58(8):1288-90. [pmid: 11971103].
86 Stern WM, Tormos JM, Press DZ, et al. Antidepressant effects of high and low frequency repetitive transcranial magnetic stimulation to the dorsolateral prefrontal cortex: a double-blind, randomized, placebo-controlled trial. J Neuropsychiatry Clin Neurosci. Spring. 2007;19(2):179-86. [pmid: 17431065].
87 O'Reardon JP, Solvason HB, Janicak PG, et al. Efficacy and safety of transcranial magnetic stimulation in the acute treatment of major depression: a multisite randomized controlled trial. Biol Psychiatry. 2007;62(11):1208-16. [pmid: 17573044].
88 Berman RM, Narasimhan M, Sanacora G, et al. A randomized clinical trial of repetitive transcranial magnetic stimulation in the treatment of major depression. Biological Psychiatry. Feb. 2000. 2000;47(4):332-7. [pmid: 10686268].
89 Bretlau LG, Lunde M, Lindberg L, et al. Repetitive transcranial magnetic stimulation (rTMS) in combination with escitalopram in patients with treatment-resistant major depression: a double-blind, randomised, sham-controlled trial. Pharmacopsychiatry. Mar. 2008;41(2):41-7. [pmid: 18311683].
90 Bortolomasi M, Minelli A, Fuggetta G, et al. Long-lasting effects of high frequency repetitive transcranial magnetic stimulation in major depressed patients. Psychiatry Res. Mar. 30. 2007;150(2):181-6. [pmid: 17303249].
91 George MS, Wassermann EM, Kimbrell TA, et al. Mood improvement following daily left prefrontal repetitive transcranial magnetic stimulation in patients with depression: a placebo-controlled crossover trial. Am J Psychiatry. Dec. 1997;154(12):1752-6. [pmid: 9396958].
92 Möller AL, Hjaltason Ó, Ívarsson Ó, et al. The effects of repetitive transcranial magnetic stimulation on depressive symptoms and the P-sub-3-sub-0-sub-0 event-related potential. Nordic Journal of Psychiatry. 2006;60(4):282-5. [pmid: 16923636].
93 Harley R, Sprich S, Safren S, et al. Adaptation of dialectical behavior therapy skills training group for treatment-resistant depression. J Nerv Ment Dis. Feb. 2008;196(2):136-43. [pmid: 18277222].
94 Kocsis JH, Gelenberg AJ, Rothbaum BO, et al. Cognitive behavioral analysis system of psychotherapy and brief supportive psychotherapy for augmentation of antidepressant nonresponse in chronic depression: The REVAMP trial. Archives of General Psychiatry. 2009;66(11):1178-88. First Author & Affiliation: Kocsis, James H. [pmid: 19884606].
95 Paykel ES, Scott J, Teasdale JD, et al. Prevention of relapse in residual depression by cognitive therapy. A controlled trial. Archives of General Psychiatry. 1999;56(9):829-35. PMID:. [pmid: 12884889].
96 Scott J, Teasdale JD, Paykel ES, et al. Effects of cognitive therapy on psychological symptoms and social functioning in residual. British Journal of Psychiatry. 2000;177(NOV.):440-6. PMID:. [pmid: 11059998].
97 Wiles NJ, Hollinghurst S, Mason V, et al. A randomized controlled trial of cognitive behavioural therapy as an adjunct to pharmacotherapy in primary care based patients with treatment resistant depression: A pilot study. Behavioural and Cognitive Psychotherapy. Jan. 2008;36(1):21-33.
98 Rush AJ, Marangell LB, Sackeim HA, et al. Vagus nerve stimulation for treatment-resistant depression: a randomized, controlled acute phase trial. Biological Psychiatry. Sep. 2005;58(5):347-54. [pmid: 16139580].
99 Avery DH, Holtzheimer PE 3rd, Fawaz W, et al. Transcranial magnetic stimulation reduces pain in patients with major depression: a sham-controlled study. J Nerv Ment Dis. May. 2007;195(5):378-81. [pmid: 17502802].
100 Moller AL, Hjaltason O, Ivarsson O, et al. The effects of repetitive transcranial magnetic stimulation on depressive symptoms and the P(300) event-related potential. Nord J Psychiatry. 2006;60(4):282-5. [pmid: 16923636].
101 Thase ME, Friedman ES, Biggs MM, et al. Cognitive therapy versus medication in augmentation and switch strategies as second-step treatments: a STAR*D report. Am J Psychiatry. 2007;164(5):739-52. [pmid: 17475733].
102 Moore RG, Blackburn IM. Cognitive therapy in the treatment of non-responders to antidepressant medication: A controlled pilot study. Behavioural and Cognitive Psychotherapy. 1997;25(3):251-9.
103 Corya SA, Williamson D, Sanger TM, et al. A randomized, double-blind comparison of olanzapine/fluoxetine combination, olanzapine, fluoxetine, and venlafaxine in treatment-resistant depression. Depress Anxiety. 2006;23(6):364-72. [pmid: 16710853].
104 Fava M, Rush AJ, Wisniewski SR, et al. A comparison of mirtazapine and nortriptyline following two consecutive failed medication treatments for depressed outpatients: a STAR*D report. Am J Psychiatry. 2006;163(7):1161-72. [pmid: 16816220].
105 Mazeh D, Shahal B, Aviv A, et al. A randomized, single-blind, comparison of venlafaxine with paroxetine in elderly patients suffering from resistant depression. Int Clin Psychopharmacol. 2007;22(6):371-5. [pmid: 17917556].
106 McGrath PJ, Stewart JW, Fava M, et al. Tranylcypromine versus venlafaxine plus mirtazapine following three failed antidepressant medication trials for depression: a STAR*D report. Am J Psychiatry. 2006;163(9):1531-41. quiz 666. [pmid: 16946177].
107 Poirier MF, Boyer P. Venlafaxine and paroxetine in treatment-resistant depression. Double-blind, randomised comparison. Br J Psychiatry. 1999:17512-6. [pmid: 10621762].
108 Shelton RC, Williamson DJ, Corya SA, et al. Olanzapine/fluoxetine combination for treatment-resistant depression: a controlled study of SSRI and nortriptyline resistance. J Clin Psychiatry. 2005;66(10):1289-97. [pmid: 16259543].
109 Nierenberg AA, Papakostas GI, Petersen T, et al. Lithium augmentation of nortriptyline for subjects resistant to multiple antidepressants. Journal of Clinical Psychopharmacology. 2003;23(1):92-5. [pmid: 12544380].
110 Shelton RC, Tollefson GD, Tohen M, et al. A novel augmentation strategy for treating resistant major depression. Am J Psychiatry. 2001;158(1):131-4. [pmid: 11136647].
111 Thase ME, Corya SA, Osuntokun O, et al. A randomized, double-blind comparison of olanzapine/fluoxetine combination, olanzapine, and fluoxetine in treatment-resistant major depressive disorder. Journal of Clinical Psychiatry. 2007;68(2):224-36. [pmid: 17335320].
112 Fang Y, Yuan C, Xu Y, et al. Comparisons of the efficacy and tolerability of extended-release venlafaxine, mirtazapine, and paroxetine in treatment-resistant depression: A double-blind, randomized pilot study in a Chinese population. Journal of Clinical Psychopharmacology. 2010;30(4):357-64. First Author & Affiliation: Fang, Yiru. [pmid: 20571433].
113 Berman RM, Marcus RN, Swanink R, et al. The efficacy and safety of aripiprazole as adjunctive therapy in major depressive disorder : A multicenter, randomized, double-blind, placebo-controlled study. J Clin Psychiatry. 2007;68(6):843-853. [pmid: 17592907].
114 Berman RM, Fava M, Thase ME, et al. Aripiprazole augmentation in major depressive disorder: a double-blind, placebo-controlled study in patients with inadequate response to antidepressants. CNS Spectr. 2009;14(4):197-206. [pmid: 19407731].
115 Janicak PG, Nahas Z, Lisanby SH, et al. Durability of acute tesponse to TMS in the treatment of major depression: relapse during a continuation pharmacotherapy extension study, Society of Biological Psychiatry Annual Meeting. 2007. May. San Diego, CA.
116 Solvason HB, Husain M, Fitzgerald PB, et al. TMS in the acute treatment of major depression: Improvments in functional status and quality of life, Society of Biological Psychiatry Annual Meeting. 2007. May. San Diego, CA.
117 Dannon PN, Dolberg OT, Schreiber S, et al. Three and six-month outcome following courses of either ECT or rTMS in a population of severely depressed individuals--preliminary report. Biol Psychiatry. Apr. 15. 2002;51(8):687-90. [pmid: 11955470].
118 Grunhaus L, Dannon PN, Schreiber S, et al. Repetitive transcranial magnetic stimulation is as effective as electroconvulsive therapy in the treatment of nondelusional major depressive disorder: an open study. Biol Psychiatry. Feb. 15. 2000;47(4):314-24. [pmid: 10686266].
119 Janicak PG, Nahas Z, Lisanby SH, et al. Durability of clinical benefit with transcranial magnetic stimulation (TMS) in the treatment of pharmacoresistant major depression: Assessment of relapse during a 6-month, multisite, open-label study. Brain Stimulation. 2010;3(4):187-99. First Author & Affiliation: Janicak, Philip G. [pmid: 20965447].
120 Scott J, Palmer S, Paykel E, et al. Use of cognitive therapy for relapse prevention in chronic depression. Cost-effectiveness study. Br J Psychiatry. Mar. 2003;182:221-7. [pmid: 12611785].
121 Paykel ES, Scott J, Cornwall PL, et al. Duration of relapse prevention after cognitive therapy in residual depression: follow-up of controlled trial. Psychol Med. 2005;35(1):59-68. [pmid: 15842029].
122 Dannon PN, Schreiber S, Dolberg OT, et al. Transcranial magnetic stimulation is effective in the treatment of relapse of depression. International Journal of Psychiatry in Clinical Practice. 2000;4(3):223-6. PMID:.
123 Schulze-Rauschenbach SC, Harms U, Schlaepfer TE, et al. Distinctive neurocognitive effects of repetitive transcranial magnetic stimulation and electroconvulsive therapy in major depression. Br J Psychiatry. May. 2005;186:410-6. [pmid: 15863746].
124 Demitrack MA, Loo CK, Maixner DF, et al. Transcranial Magnetic Stimuatlin (TMS) in the Treatment of Pharmacoresistant Major Depression: Examination of Cognitive Function During Acute Treatment. Society for Biological Psychiatry Annual Meeting and New Research Sessions of the American Psychiatric Association Annual Meeting. 2009 May. Vancouver B.C., San Francisco, CA. 2009.
125 Janicak PG, O'Reardon JP, Sampson SM, et al. Transcranial magnetic stimulation in the treatment of major depressive disorder: a comprehensive summary of safety experience from acute exposure, extended exposure, and during reintroduction treatment. J Clin Psychiatry. 2008;69(2):222-32. [pmid: 18232722].
126 O'Connor M, Brenninkmeyer C, Morgan A, et al. Relative effects of repetitive transcranial magnetic stimulation and electroconvulsive therapy on mood and memory: a neurocognitive risk-benefit analysis. Cogn Behav Neurol. Jun. 2003;16(2):118-27. [pmid: 12799598].
127 Frith CD, Stevens M, Johnstone EC, et al. Effects of ECT and depression on various aspects of memory. Br J Psychiatry. 1983:142610-7. [pmid: 6882984].
128 Frith CD, Stevens M, Johnstone EC, et al. A comparison of some retrograde and anterograde effects of electroconvulsive shock in patients with severe depression. Br J Psychol. 1987;78(Pt 1):53-63. [pmid: 3828659].
129 Jorge RE, Moser DJ, Acion L, et al. Treatment of vascular depression using repetitive transcranial magnetic stimulation. Arch Gen Psychiatry. Mar. 2008;65(3):268-76. [pmid: 18316673].
130 Jorge RE, Robinson RG, Tateno A, et al. Repetitive transcranial magnetic stimulation as treatment of poststroke depression: a preliminary study. Biol Psychiatry. Feb. 15. 2004;55(4):398-405. [pmid: 14960293].
131 Aas IH. Global assessment of functioning (GAF): properties and frontier of current knowledge. Ann Gen Psychiatry. 2010;9(1):20. [pmid: 20459646].
132 Leon AC, Solomon DA, Mueller TI, et al. The range of impaired functioning tool (LIFE-RIFT): a brief measure of functional impairment. Psychol Med. 1999;29(4):869-78. [pmid: 10473314].
133 Ware JE, Snow KK, Kolinski M, et al. SF-36 Health Survey manual and interpretation guide. Boston, MA. The Health Institute, New England Medical Centre. 1993.
134 Wisniewski SR, Rush AJ, Bryan C, et al. Comparison of quality of life measures in a depressed population. The Journal of Nervous and Mental Disease. 2007;195(3):219-25. [pmid: 17468681].
135 Endicott J, Nee J, Harrison W, et al. Quality of Life Enjoyment and Satisfaction Questionnaire: A New Measure. 1993.
136 Achard S, Chignon JM, Poirier-Littre MF, et al. Social adjustment and depression: value of the SAS-SR (Social Adjustment Scale Self-Report). Encephale. 1995;21(2):107-16. [pmid: 7781581].
137 Endicott J, Spitzer RL, Fleiss JL, et al. The global assessment scale. A procedure for measuring overall severity of psychiatric disturbance. Archives of General Psychiatry. 1976;33(6):766-71. [pmid: 938196].
138 Avery DH, Isenberg KE, Sampson SM, et al. Transcranial magnetic stimulation in the acute treatment of major depressive disorder: clinical response in an open-label extension trial. J Clin Psychiatry. Mar. 2008;69(3):441-51. [pmid: 18294022].
139 Loo CK, Taylor JL, Gandevia SC, et al. Transcranial magnetic stimulation (TMS) in controlled treatment studies: are some “sham” forms active?. Biological Psychiatry. 2000;47(4):325-31. [pmid: 10686267].
140 George MS, Nahas Z, Borckardt JJ, et al. Vagus nerve stimulation for the treatment of depression and other neuropsychiatric disorders. Expert Review of Neurotherapeutics. 2007;7(1):63-74. [pmid: 17187498].
141 Ware JE Jr, Sherbourne CD. The MOS 36-item short-form health survey (SF-36). I. Conceptual framework and item selection. Medical Care. 1992;30(6):473-83. [pmid: 1593914].
142 Kind P, editor. The EuroQol instrument: An index of health-related quality of life. Quality of life and pharmacoEconomics in clinical trials. 2. Philadelphia. Lippincott-Raven Publishers. 1996.
143 Lisanby SH, Luber B, Schlaepfer TE, et al. Safety and feasibility of magnetic seizure therapy (MST) in major depression: randomized within-subject comparison with electroconvulsive therapy. Neuropsychopharmacology. Oct. 2003;28(10):1852-65. [pmid: 12865903].
144 White PF, Amos Q, Zhang Y, et al. Anesthetic considerations for magnetic seizure therapy: a novel therapy for severe depression. Anesth Analg. 2006;103(1):76-80. table of contents. [pmid: 16790630].
145 Kirov G, Ebmeier KP, Scott AI, et al. Quick recovery of orientation after magnetic seizure therapy for major depressive disorder. Br J Psychiatry. Aug. 2008;193(2):152-5. [pmid: 18670002].
146 Malone DA Jr, Dougherty DD, Rezai AR, et al. Deep brain stimulation of the ventral capsule/ventral striatum for treatment-resistant depression. Biol Psychiatry. 2009;65(4):267-75. PMID:. [pmid: 18842257].
147 McNeely HE, Mayberg HS, Lozano AM, et al. Neuropsychological impact of Cg25 deep brain stimulation for treatment-resistant depression: preliminary results over 12 months. J Nerv Ment Dis. May. 2008;196(5):405-10. [pmid: 18477883].
148 Mayberg HS, Lozano AM, Voon V, et al. Deep brain stimulation for treatment-resistant depression. Neuron. Mar. 3. 2005;45(5):651-60. [pmid: 15748841].
149 Kenny MA, Williams JM. Treatment-resistant depressed patients show a good response to Mindfulness-based Cognitive Therapy. Behav Res Ther. Mar. 2007;45(3):617-25. [pmid: 16797486].