# Peer Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this report and provided us with constructive feedback. The peer reviewers were asked to provide comments on the content, structure, and format of the evidence report. Their comments and suggestions formed the basis of our revisions to the evidence report. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report.

Stuart Eisendrath, M.D.

Professor of Clinical Psychiatry

Director of Clinical Services

Director, Depression Center at Langley Porter

University of California at San Francisco

San Francisco, California

Edward Friedman, Ph.D.

Associate Director of the Mood Disorders Treatment and Research Program

Western Psychiatric Institute and Clinic

University of Pittsburgh Medical Center

Associate Professor of Psychiatry

University of Pittsburgh

Ronald Glick, M.D.

Department of Psychiatry

University of Pittsburgh School of Medicine

Pittsburgh, PA

Steven D. Hollon, Ph.D.

Professor of Psychology

Psychological Services

Vanderbilt University

Sarah H. Lisanby, M.D.

Director, Division of Brain Stimulation & Therapeutic Modulation

Columbia University College of Physicians and Surgeons

New York State Psychiatric Institute

New York, New York

Evette Ludman, Ph.D.

Senior Research Associate

Group Health Institute

Group Health Cooperative

Seattle, Washington

Glenda M. MacQueen, Ph.D., M.D.

Head, Dept. Mood Disorders Research Program

Psychiatry and Behavioral Neurosciences

McMasters University, Hamilton, Ontario

Andrew Alan Nierenberg, M.D.

Professor of Psychiatry, Harvard

Massachusetts General Hospital

Eric Plakun, M.D.

Psychiatrist

Austin Riggs Center

Stockbridge, Massachusetts

Greg Simon, M.D., M.P.H.

Senior Investigator

Group Health Cooperative

Center for Health Studies

Seattle, Washington