# Methods

In this chapter, we document the procedures that the Evidence-based Practice Center (EPC) used to develop this comparative effectiveness review (CER) on nonpharmacologic treatments for adults with treatment-resistant depression (TRD). We briefly describe the topic development process below. We then document our literature search and retrieval process and describe methods of abstracting relevant information from the eligible articles to generate evidence tables. We also document our criteria for rating the quality of individual studies and for grading the strength of the evidence as a whole.

## Topic Development

The topic of this CER and preliminary questions arose through an open process involving the public, the Scientific Resource Center (SRC) for the Effective Health Care Program of the Agency for Healthcare Research and Quality (AHRQ) at Oregon Health and Science University, and various stakeholder groups. Our EPC was asked to develop provisional Key Questions (KQs) based on the issues submitted by the nominator of the topic. We conducted a preliminary literature review and worked with key informants to develop a set of provisional KQs. These KQs were posted by AHRQ for public comment before they were assigned to the RTI International-University of North Carolina EPC for this full CER.

## Technical Expert Panel

In designing the study questions and methodology at the topic development stage, we consulted several technical and content experts, seeking broad expertise and perspectives. We worked with seven key informants and all were invited to participate in the Technical Expert Panel (TEP) for the full CER. Five accepted, and in one case a replacement from the consumer organization was made because the original person was no longer with the organization. In addition, we invited an expert in psychotherapy and another psychiatrist conducting a similar evidence review on pharmacotherapy options after one failed treatment, creating a total of eight members (listed in the Acknowledgements). We note that two TEP members had undisclosed conflicts of interest (COIs) related to the repetitive transcranial magnetic stimulation (rTMS) device that were identified during the course of the project. Upon further inquiry and clarification of the specifics of the form, both individuals filed amended COI forms.

To ensure robust, scientifically relevant work, we called on the TEP to provide reactions to work in progress and advice on substantive issues or possibly overlooked areas of research. Specifically, TEP members participated in conference calls and discussions through e-mail to:

- Review the KQs and analytic framework at the beginning of the project;
- Discuss the preliminary assessment of the literature, including inclusion/exclusion criteria and the review of the protocol; and
- Provide input on the information and categories included in evidence tables.

Our KQs were posted on AHRQ's Effective Health Care Web site on December 9, 2009. After discussions with the TEP, we added an additional question, KQ 1b, as described in the Introduction chapter.

## Literature Search

### Databases and Search Terms

To identify articles relevant to each of the six KQs defined in the Introduction chapter, we searched MEDLINE, Embase, the Cochrane Library, PsycINFO, and the International Pharmaceutical Abstracts. The full search strategy is presented in Appendix A. We used Medical Subject Headings (MeSH or MH) as search terms when available as well as key words when appropriate. The first step was to locate all articles on depression in human adults published in English. We combined terms for treatment-resistant depression, including the terms refractory, resistant, and drug resistance. The search was further narrowed to specific pharmacological and nonpharmacological treatments. Nonpharmacological interventions included socioenvironmental therapy, interpersonal psychotherapy (IPT), psychotherapy, cognitive therapy, cognitive behavioral therapy (CBT), electroconvulsive therapy (ECT), repetitive transcranial magnetic stimulation (rTMS), and vagus nerve stimulation (VNS). We searched for systematic reviews, clinical controlled trials, and nonexperimental studies in which the investigator did not assign group allocation. Sources were searched from 1980 to November 18, 2010.

We used the National Library of Medicine publication type tags to identify reviews, randomized controlled trials (RCTs), and meta-analyses. We also manually searched reference lists of pertinent review articles and letters to the editor. We imported all citations into an electronic database (EndNote X3). Additionally, we hand-searched the Center for Drug Evaluation and Research database to identify unpublished research submitted to the U.S. Food and Drug Administration.

AHRQ SRC staff contacted device manufacturers and invited them to submit dossiers, including citations. We reviewed dossiers received from Cyberonics and Neuronetics. The SRC also provided our EPC with the results of their gray literature search: relevant articles, conference proceedings, and meeting abstracts to assist our center to identify other eligible studies that may not have been captured in the literature search.

### Analytic Framework

Based on the six KQs, we developed an analytic framework to guide the systematic review (Figure 3). Specifically, the first two KQs pertain to the efficacy and effectiveness of obtaining (KQ 1) and maintaining (KQ 2) response and remission using these nonpharmacologic treatments; KQ 1 addresses the acute phase of treatment and KQ 2 the continuation or maintenance phases of treatment (as depicted in Figure 3). KQ 3 addresses response and remission for psychiatric subtypes of TRD (e.g., coexisting anxiety) and KQ 5 focuses on certain population subgroups (e.g., the elderly). KQ 4 focuses on safety and tolerability issues—that is, harms—with each of the interventions. Finally, KQ 6 looks at how these interventions affect other health outcomes, such as quality of life.

Figure 3 Analytic framework for nonpharmacologic interventions for treatment-resistant depression

Figure 3 is an analytic framework that depicts the events that adults with a current episode of treatment-resistant depression experience while undergoing treatment. The interventions are nonpharmacologic interventions for treatment-resistant depression. The first set of outcomes are utilized to determine efficacy and effectiveness by obtaining and maintaining response and remission in the acute phase. These outcomes are also considered among certain population subgroups as well as for psychiatric subtypes of TRD. The second set of outcomes are to determine the continuation of the maintenance phases of treatment. These outcomes are also considered among certain population subgroups. Safety and tolerability are considered for the interventions of interest. Finally quality of life, morbidity, mortality, and other health outcomes are considered in terms of the interventions.

## Study Selection

To summarize, interventions included for one or more of the key questions (KQs) are:

- Nonpharmacologic therapies, for KQs 1-6:
  ◦ ECT
  ◦ rTMS
  ◦ VNS
  ◦ Evidence-based psychotherapy, specifically cognitive therapy (CBT or IPT)
- Pharmacologic,47 for KQ 1b only, at least one of the antidepressants listed below:
  ◦ Selective serotonin reuptake inhibitors (SSRIs): citalopram, escitalopram, fluoxetine, fluvoxamine, paroxetine, sertraline
  ◦ Serotonin-norepinephrine reuptake inhibitors: desvenlafaxine, duloxetine, mirtazapine, venlafaxine
  ◦ Serotonin modulators: nefazodone and trazodone
  ◦ Tetracyclic: mirtazapine
  ◦ Other antidepressants: bupropion
  ◦ Tricyclic antidepressants: amitriptyline, clomipramine, desipramine, doxepin, imipramine, maprotiline, mianserin, nortriptyline
  ◦ Monoamine oxidase inhibitors (MAOIs): phenelzine, tranylcypromine
  ◦ Augmentation strategies with methylphenidate; T4/cytomel; liothyronine; buspirone; lithium or amilsupride; apripazole; olanzapine; quetiapine; risperidone; ziprasidone.

For each KQ, we specified inclusion and exclusion criteria for studies and specified the outcome measures of interest (Table 2). For efficacy and effectiveness (all KQs except KQ 4), we first focused on head-to-head RCTs comparing one intervention with another. This body of work provides direct evidence about the comparisons. When sufficient head-to-head evidence was unavailable, we evaluated placebo- or sham-controlled evidence; in some cases, studies might have used “treatment as usual” as the control arm. In any of these cases, the evidence provides only indirect evidence. Systematic evidence reviews or meta-analyses based on a systematic literature search were eligible for inclusion for each KQ. For reviewing adverse events (KQ 4), per our standard approach, we include observational studies. Finally, given the dearth of randomized controlled data that our preliminary review suggested was available for KQ 3 on psychiatric subtypes, KQ 5 on subgroups, and KQ 6 on quality of life, for these KQs we included observational studies (limited to prospective and retrospective cohort studies and case control studies). We do not formally distinguish efficacy from effectiveness trials.

Table 2 Key questions, outcomes, and study eligibility by key question

Key Question and Outcomes | Study Eligibility Criteria (Inclusion and Exclusion Criteria)
KQ 1a and 1b Efficacy and effectiveness; - Outcomes; - Response; - Remission; - Measurement Scales; - Hamilton Rating Scale for Depression Scale (HAM-D); - Montgomery-Åsberg Depression Rating Scale (MADRS); - Beck Depression Inventory (BDI); - Inventory of Depressive Symptomatology; - Clinical Global Impression (CGI); - Other relevant scales if none of the above is reported (e.g., Patient Health Questionnaire [PHQ-9]) | Study design KQ 1a:; - RCTs of nonpharmacologic vs. nonpharmacologic; - RCTs of nonpharmacologic vs. pharmacologic (an antidepressant, with or without additional pharmacologic agent[s]); - Good- or fair-quality meta-analyses or systematic evidence reviews; KQ 1b:; - RCTs of nonpharmacologic vs. placebo or sham; - RCTs of pharmacologic (an antidepressant, with or without additional pharmacologic agent[s]) vs. placebo or sham; - Good- or fair-quality meta-analyses; Minimum study duration; - Any duration; Sample size; - No minimum
KQ 2 Maintenance of response or remission (or prevention of relapse or recurrence); - Outcomes; - Relapse (continuation phase); - Recurrence (maintenance phase); - Measurement Scales; - All efficacy/effectiveness scales (see KQ 1 above) | Study design; - RCTs of nonpharmacologic vs. nonpharmacologic; - RCTs of nonpharmacologic vs. placebo or sham; - RCT designs include continued treatment for prevention or assessment of duration of effect after treatment stopped; - Good- or fair-quality meta-analyses or systematic evidence reviews; Minimum study duration; - ≥ 1 month for relapse prevention; - ≥ 3 months for recurrence prevention; Sample size; - No minimum
KQ 3 Efficacy and effectiveness by subtype; - Outcomes; - Response; - Remission; - Measurement Scales; - All efficacy/effectiveness scales (see KQ 1 above); - Symptom Subtypes; - Psychotic-paranoia/hallucinations; - Melancholic; - Atypical; - Postpartum | Study design; - RCTs of nonpharmacologic vs. nonpharmacologic; - RCTs of nonpharmacologic vs. placebo or sham; - Good- or fair-quality meta-analyses or systematic evidence reviews; - Observational studies (limited to prospective and retrospective cohort studies, case control studies); Minimum study duration; - Any duration; Sample size; - No minimum
KQ 4 Safety, adverse events, and adherence; - Outcomes; - Neurocognitive; ◦ Amnesia; ◦ Memory loss; - Headaches; - Postoperative complications; - Other reported events; - Discontinuations; - Adherence/compliance; - Measurement Scales; - All reported adverse events measurement scales; - Discontinuations (overall and attributed to adverse events); - Adherence or compliance measures | Study design; - RCTs of nonpharmacologic vs. nonpharmacologic; - RCTs of nonpharmacologic vs. placebo or sham; - Good- or fair-quality meta-analyses; - Observational studies (limited to prospective and retrospective cohort studies, case control studies); Minimum study duration; - Any duration; Sample size; - No minimum, case reports excluded
KQ 5 Population subgroups; - Outcomes; - Response/remission; - Relapse/recurrence; - Adverse events; - Discontinuations; - Measurement Scales; - All efficacy/effectiveness scales (see KQ 1 above); - All reported adverse events measurement scales (see KQ 4 above); - Discontinuations and adherence rates; - Population Subgroups; - Age; - Medical comorbidity; - Race or ethnicity | Study design; - RCTs of nonpharmacologic vs. nonpharmacologic; - RCTs of nonpharmacologic vs. placebo or sham; - Good- or fair-quality meta-analyses; - Observational studies (limited to prospective and retrospective cohort studies, case control studies); Minimum study duration; - Any duration; Sample size; - No minimum, case reports excluded
KQ 6 Health-related outcomes; - Outcomes; - Quality of life; - Satisfaction/enjoyment; - Physical or mental functioning; - Work productivity or employment; - Measurement Scales; - Global Assessment of Functioning Ability (GAF); - Quality of Life Enjoyment and Satisfaction Questionnaire (Q-LES-Q); - Medical Outcomes Study Short Form (SF-36, SF-12 or others); - Employment/productivity scales; - Other relevant measures | Study design; - RCTs of nonpharmacologic vs. nonpharmacologic; - RCTs of nonpharmacologic vs. placebo or sham; - Good- or fair-quality meta-analyses; - Observational studies (limited to prospective and retrospective cohort studies, case control studies); Minimum study duration; - Any duration; Sample size; - No minimum

KQ = key question; RCT = randomized controlled trial

Two people independently reviewed article abstracts using the criteria presented in Appendix B for Level One. If both reviewers agreed that the study did not meet eligibility criteria, we excluded it; otherwise it moved forward to the next step for full-text review, Level Two. We retrieved the full articles for all studies retained at this stage.

Two reviewers then independently reviewed the full-text articles and applied a more detailed set of inclusion criteria; these involved explicit reasons for exclusion, such as wrong intervention, and wrong or no comparison group. Appendix B includes copies of all reviewer forms. We resolved conflicts about inclusion at this stage through consensus, with conflicts adjudicated by a third party. Studies excluded at this stage, along with reasons for exclusion, are listed in Appendix C.

For this review, results from well-conducted, valid head-to-head trials—that is, direct comparisons—provide the strongest evidence to compare treatments with respect to efficacy and harms. The many possible comparisons, set out in the Introduction chapter, are complex; in some cases, studies compared a treatment with a combination of that treatment and a second intervention. We defined head-to-head trials as those comparing one treatment with another treatment either by itself or in combination with other interventions.

We did not examine placebo-controlled or sham-controlled trials in detail if a sufficient number of head-to-head trials were available. If the published head-to-head evidence was limited, we reviewed placebo-controlled trials to provide an overview of efficacy. For harms (i.e., evidence pertaining to tolerability and adverse events), we examined data from both experimental and observational studies.

We did not set any minimum criteria for study duration or sample size, though case reports were excluded when observational study designs were allowed. The exception to this involved relapse and recurrence prevention studies, for which we required at least 1 and 3 months of followup, respectively.

We reviewed studies with health outcomes as primary outcome measures. Outcomes for efficacy or effectiveness, for example, were a decrease in depressive severity, treatment response and remission, quality of life, relapse, functional capacity, and hospitalization. We reviewed response and remission when based on changes in scores on depression scales as proxies for health outcomes (e.g., 50 percent improvement of depression scores for response). For harms, we looked for both overall and specific outcomes related to neurocognitive functioning, specific adverse events (e.g., amnesia, memory loss, headache), and procedure-related complications, recorded systematically and spontaneously, as well as tolerability as reflected by withdrawals and withdrawals attributable to adverse events.

## Data Extraction and Analytic Strategy

We designed and used a structured data abstraction form to ensure consistency of data abstraction and quality appraisal for each study (reproduced in Appendix B). All data abstraction originally employed SRS 4.0 Mobius Analytics (available at: www.mobiusanalytics.com/e/index.cfm). Trained reviewers abstracted data from each included study into predesigned evidence tables for each KQ; they also assigned an initial quality rating (described below). A senior reviewer read each abstracted article, evaluated the accuracy and completeness of the data abstraction, and independently did a second quality rating. Final evidence tables can be found in Appendix D.

We abstracted data on study design, baseline population characteristics, specifications of the intervention, and relevant outcome assessments for both efficacy and harms. We abstracted data for the efficacy and quality-of-life outcome assessments when the studies used validated measures. We also abstracted data on compliance, attrition, and harms. Finally, we recorded whether analyses were done according to intention-to-treat methods if such information was available in the articles. A detailed list of the data elements abstracted is presented in Appendix B.

### Treatment Resistant Depression Definition and Tier Classification

As already noted, the definitions of TRD vary along several dimensions: How many previous treatment failures are considered? What types of treatments failed? Were dose and duration of previous treatments adequate? Were the failures during the current episode or over a lifetime? Moreover, the populations included in clinical studies differ by numerous factors. In regard to the variability of the definitions used in studies of TRD, as laid out in the Introduction chapter, we extracted specific information to create the three-tiered classification system used in presenting results in the Results chapter. We specifically collected data on the study's definition of a failed “trial” (i.e., a treatment in this context). These variables included a specific drug or drug class failed, the specified duration and/or dose of an “adequate” trial, the number of failed trials (whether in the current episode or in a previous, “lifetime,” episode) required for inclusion, and baseline characteristics (i.e., the mean number of failed trials and other pertinent descriptors) of the sample.

Although our working definition of TRD is two or more treatment failures, we realize that many studies involving TRD populations often do not use this definition when formulating their inclusion criteria and that these criteria may not accurately reflect the average number of failed antidepressant trials for a study population. For example, although some studies may require only a single antidepressant failure for a participant to be included in a study, the inclusion criteria may not accurately indicate the average number of antidepressant failures for the study population, which could be higher than the cut point set by study inclusion criteria.

When devising the analytic strategy for this report, variation in study inclusion criteria and the overlap in the actual number of antidepressant failures were considered. As a function of our preliminary literature review, we realized that evolving definitions of TRD might prevent inclusion of studies with data relevant to our population of interest. For example, studies conducted at a time when resistance was understood to be one or more treatment failures might have nearly a complete population of patients with TRD (two or more treatment failures), but because the analyses did not allow results to be stratified by having two or more treatment failures, such a study would be excluded. Also, studies in which the number of prior treatment failures was not specified but where the likelihood of TRD was high, such as with many ECT trials, would also be excluded. We believed that not including such studies would not accurately reflect the available evidence base for TRD.

Accordingly, we considered options and discussed possible approaches with our TEP, who supported the use of a tiered study classification system. We have attempted to maintain our focus on study populations meeting our TRD definition (≥ 2 antidepressant failures) while not excluding potentially relevant evidence.

Our approach to stratifying the literature—into three “tiers”—is highlighted in Table 3. We primarily differentiate studies based on how investigators for the included studies defined TRD:

- Tier 1 evidence: involves studies requiring failure to recover following two or more adequate antidepressant treatment trials (Tier 1, our working definition of TRD).
- Tier 2 evidence: involves studies requiring patients to have one or more failed adequate antidepressant treatment trials; may include both those with only one prior treatment failure in addition to those with two or more failed trials. By virtue of including those with only one failure, on average this group has an overall lesser degree of treatment resistance than TRD patients (Tier 1).
- Tier 3 evidence: involves studies where the number of prior failed treatments was not specified but the clinical situation suggested a high probability of patients having two or more failed prior antidepressant trials; these data have probable relevance to TRD. For example, an included study may refer to TRD without characterizing it, or the clinical presentation may strongly suggest two or more prior treatment failures. Studies that did not specify the number of failed treatments but noted that all subjects were referred for ECT were included in this tier.

Table 3 Relevance to TRD per CER protocol by Tiers of evidence pertaining to populations involving varying proportions of treatment-resistant depression

Population | Tier 1. TRD per CER Protocol (All Patients Required to Have ≥ 2 Treatment Failures) | Tier 2. All Patients Required to Have ≥ 1 Prior Treatment Failures | Tier 3. Involves Those With Probable TRD (But Number of Treatment Failures not Specified)
MDD alone | All MDD patients who failed ≥ 2 previous treatments | All MDD patients who failed ≥ 1 previous treatment | All MDD patients with TRD not defined
Mixed MDD and bipolar disease, with bipolar patients constituting > 0% but ≤ 20% of the study population | MDD/bipolar mix who failed ≥ 2 previous treatments | MDD/bipolar mix who failed ≥ 1 previous treatment | MDD/bipolar mix with TRD not defined

CER = comparative effectiveness review; MDD = major depressive disorder; TRD = treatment-resistant depression

### Psychiatric Diagnosis

Also, as described in the Introduction chapter, we included study populations of patients with major depressive disorder (MDD) and study populations that include a small number of patients with bipolar disorder. We explicitly extracted data regarding the psychiatric diagnosis—that is, MDD or bipolar disorder—to allow us to limit the percentage of patients with a bipolar TRD to ≤ 20 percent, a proportion that we determined would be unlikely to influence the outcomes from what was expected for an MDD TRD population. If the study clarified whether the included bipolar patients were Type 1 (with manic episodes) or Type 2 (with hypomanic episodes), we collected this information.

### Nonpharmacologic Intervention Treatment Characteristics

During data abstraction, characteristics of each mode of nonpharmalogical intervention that affected treatment dose or intensity were collected and used in our analytic approach. Parameter variables were unique for each mode of intervention. For ECT, data were collected on the location of the stimuli (e.g., unilateral/bilateral), treatment intensity (e.g., as a function of seizure threshold), number of treatments per week, and mean number of treatment sessions. In the Results chapter, ECT implementation for an intervention group is described using the proportion receiving bilateral stimulation and the mean number of treatment sessions received; additional treatment description parameters are listed in the evidence tables (Appendix D).

For rTMS, data were abstracted on the location of stimuli (e.g., left or right dorsolateral prefrontal cortex); frequency (e.g., hertz [Hz]) and intensity (e.g., as a function of motor threshold) of the stimuli; stimuli or pulses per session (abbreviated “pps”); total number of sessions; and duration of treatment (in weeks). These variables were not always presented in this fashion within our included studies. The following formula was used to calculate pps when the number of treatments per week was not explicitly provided: frequency (Hz) times the duration of each train (seconds) times the number of trains equals pps.21

A range of treatment parameters for both active and sham stimulations are used in rTMS efficacy studies. In the treatment of depression, stimuli are most often applied at either a high frequency (> 1 Hz) to the left or low frequency (≤ 1 Hz) to the right dorsolateral prefrontal cortex.21 To simplify reporting in the Results chapter, the location of stimulation and frequency is specified only in studies deviating from these conventions. All other interventions are described as either high rTMS or low rTMS and complete descriptions of all rTMS stimulation parameters as provided in individual studies are reported in the evidence tables (Appendix D).

Some methods of sham rTMS have been shown to have a smaller but noteworthy amount of active stimulation.53,54 If an included study used one of these methods of sham stimulation, investigators assessed the possibility that it affected the results of the study with potential issues acknowledged in the description of the results. Full descriptions of all sham stimulation parameters are found in the evidence tables (Appendix D).

For VNS, data were collected on the frequency (Hz), pulse width (in seconds), on/off cycle schedule, and duration of treatment. Only treatment parameters outside of the standard range are described in the results; full intervention methodologies, including sham stimulation procedures, are presented in the evidence tables (Appendix D).

Lastly, for psychotherapeutic interventions, data were collected on the method of therapy implementation (i.e., individual or group therapy), content of the curriculum (e.g., cognitive-based therapy), intensity of the treatment (in sessions per week), total number of sessions, and treatment duration (in weeks). Psychotherapeutic interventions are defined by curriculum content in the results; other parameters are reported in the evidence tables (Appendix D).

### Antidepressant Medication Treatment Strategy

In addition to the nonpharmacologic interventions used in studies, investigators used different strategies for managing patients' antidepressant pharmacotherapy that included antidepressants and augmenting agents such as antipsychotics and mood stabilizers. All included studies were categorized into one of five groups according to how the antidepressant pharmacotherapy is addressed as part of a study design. Antianxiety medications were allowed by some studies; however, these medications were not assessed as part of the antidepressant strategy categorization as there is no evidence basis supporting their benefit as an augmentation agent.

Switch studies are those in which all patients discontinued their prior antidepressant treatment before initiating their next step treatment. Other studies allowed patients to continue their prior antidepressant pharmacotherapy and initiated next step treatment as an add-on or augmentation to their current treatment; these treatment strategies were termed augmentation strategies. In some augmentation studies, a small proportion of patients were not taking any psychotropic medications before or during the trial. The inclusion of such patients is acknowledged in the study description.

A third set of studies used both switch and augmentation strategies and were categorized as mixed. Two types of mixed studies exist in the included literature. One group of studies encourages but does not require patients to discontinue their antidepressant medications, resulting in a study population that contains both switchers and augmenters in all study groups. Studies that allow different antidepressant medication strategies within research groups are called mixed-within. Other studies compare patients who switch to patients who augment; these studies use a mixed antidepressant medication strategy with between-group differences and are called mixed-between.

In another subset of studies, all patients initiated a new psychotropic medication at the same time in which active groups began the nonpharmacologic intervention. This strategy was termed combination treatment. Lastly, in a small group of studies, medications were not limited or initiated by the study (e.g., patients sought treatment as usual, which allowed them to change medications or continue the same regimen at the discretion of their treating doctor). This group of studies was described as having an unlimited psychotropic medication strategy. A small number of studies allowed (or disallowed) antidepressant medications and potential augmenting agents differently (e.g., antidepressants were discontinued but patients were allowed to continue antipsychotics); pharmacologic strategies of these studies are described in the text and summary tables. Details of each study's antidepressant medication strategy are provided in the evidence tables (Appendix D).

### Disease Severity

Lastly, to enable us to examine differences based on disease severity, we grouped baseline scores into three categories: none to mild, moderate, and severe to very severe (Table 4).55

Table 4 Categories of depressive severity

Instrument | None/Mild | Moderate | Severe/Very Severe
HAM-D_17_ | ≤ 13 | 14–19 | ≥ 20
HAM-D_21_ | ≤ 15 | 16–22 | ≥ 23
HAM-D_24_ | ≤ 18 | 19–26 | ≥ 27
MADRS | ≤ 19 | 20–34 | ≥ 35
BDI | ≤ 18 | 18–29 | ≥ 30
QID-SR | ≤ 10 | 11–15 | ≥ 16

BDI = Beck Depression Inventory; HAM-D = Hamilton Rating Scale for Depression; MADRS = Montgomery-Åsberg Depression Rating Scale; QID-SR = Quick Inventory of Depressive Symptomatology—Self-Report.

## Quality Assessment

To assess the quality (internal validity or risk of bias) of all included studies, we used predefined criteria based on those described in the AHRQ Methods Guide for Comparative Effectiveness Reviews (ratings: good, fair, poor).56 Two independent reviewers assigned quality ratings. They resolved any disagreements by discussion and consensus or by consulting with a third reviewer.

Elements of quality assessment for trials included, among others, the methods used for randomization, allocation concealment, and blinding; the similarity of compared groups at baseline; maintenance of comparable groups; overall and differential loss to followup; and the use of intention-to-treat analysis. We assessed observational studies based on the potential for selection bias (methods of selection of subjects and loss to followup), potential for measurement bias (equality, validity, and reliability of ascertainment of outcomes), adjustment for potential confounders, and statistical analysis.

In general terms, a “good” study has the least bias, and results are considered to be valid. We rated studies that met all criteria as good quality. “Fair” studies presumably fulfilled all quality criteria but did not report their methods to an extent that answered all of our questions. A fair study is susceptible to some bias but probably not sufficient to invalidate its results. The fair-quality category is likely to be broad, so studies with this rating will vary in their strengths and weaknesses. A “poor” rating indicates significant bias (stemming from, e.g., serious errors in design, analysis reporting large amounts of missing information, or discrepancies in reporting) that may invalidate the study's results. Studies that had a fatal flaw (defined as a methodological shortcoming that leads to a high probability of bias) in one or more categories were rated poor quality.

Poor-quality studies and reasons for that rating are presented in Appendix F. In this CER, we excluded poor-quality studies from our analyses if there were enough good or fair studies with significant findings. In some cases, a poor study may offer the only pertinent information about an important outcome or comparison, and we may comment on it in the relevant section of Results but it will not be included in summary tables there.

## Applicability Assessment

Using the parameters for evaluation on guidance provided by AHRQ's Methods Guide for Comparative Effectiveness Reviews,57 we evaluated the applicability of the studies included and evaluated in this CER. Applicability is essentially the generalizability or external validity of the studies included in the evidence base. We evaluated applicability using a qualitative assessment of the population, intervention/treatment, comparator, outcomes measured, timing of followup, and setting. We specifically considered whether populations enrolled in these trials or studies differed from target populations as laid out above, whether studied interventions are comparable with those in routine use, whether comparators reflect best alternatives, whether measured outcomes reflect the most important clinical outcomes, whether followup was sufficient, and whether study settings were representative of most settings.

## Grading Strength of a Body of Evidence

We evaluated the strength of evidence based on the AHRQ Methods Guide for Comparative Effectiveness Reviews.56 Strength of evidence is graded only for major comparisons and major outcomes for the topic at hand. The strength of evidence for each outcome or comparison that we graded incorporates scores on four mandatory domains: risk of bias, consistency, directness, and precision; it can also reflect ratings for other domains that can be factored in when relevant (e.g., dose-response relationships). As described in Owens et al., the evaluation of risk of bias includes assessment of study design and aggregate quality of studies.56 We judged good-quality studies with strong designs to result in evidence with low risk of bias. We graded evidence as consistent when effect sizes across studies were in the same direction and had a narrow range. When the evidence linked the interventions directly to health outcomes, we graded the evidence as being direct. For active versus sham control comparisons, we graded the evidence as direct for general efficacy, which should not be interpreted as direct comparative effectiveness for the head-to-head comparisons considered in this report (e.g., rTMS vs. VNS, rTMS vs. ECT). For the main head-to-head comparisons for this report (ECT, rTMS, VNS, and psychotherapy), we graded evidence as being precise when results had a low degree of uncertainty. We had two separate reviewers evaluate the overall strength of evidence for each major outcome based on a qualitative assessment of strength of evidence for each domain and reconciled all disagreements. The levels of strength of evidence are shown in Table 5. We present our strength of evidence findings for TRD (Tier 1 studies) in our overview sections.

Table 5 Strength of evidence grades and their definitions

Grade | Definition
High | High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

## Data Synthesis

Although we use the tiers as a guide to describe all the included evidence, our primary focus is on the populations with a Tier 1 TRD definition (two or more previous treatment failures). Some studies do not clarify whether failures occurred in a “current” episode or during one or more previous episode(s) (which can be characterized as over a “lifetime”). For that reason, our tiers may include a mix of studies that assess failing treatments in the current episode or failing treatments over a more extended period that may involve more than one episode. We highlight this distinction as appropriate. We also highlight other aspects of how treatment resistance, diagnosis, or severity of illness might vary.

For each KQ, we first present an overview of the particular comparison, including the strength of evidence findings for the Tier 1 studies. This section is followed by a key points section, which highlights important findings from the relevant comparisons, first for Tier 1 and then for Tiers 2 and 3. Finally, we present a detailed analysis section, which describes the individual studies, beginning with Tier 1 and followed by Tiers 2 and 3, in more detail. If possible, we report quantitative analyses as described below.

As described above, a complex and broad array of factors have the potential to shape the answers to the KQs. Throughout this report we synthesized the literature qualitatively.

If data were sufficient, we also augmented findings with quantitative analyses. We first quantitatively synthesized results for our primary focus, TRD (Tier 1) studies. Further, to assess how consideration of Tiers 2 and 3 affects Tier 1 findings alone, we also quantitatively synthesized results for Tiers 1, 2, and 3 combined to allow a comparison with Tier 1 alone.

We conducted meta-analyses of data for comparisons involving trials that were fairly homogenous in study populations, treatment intervention, and outcome assessments. For efficacy, we used three outcome measures:

1. The weighted mean difference of changes on the Hamilton Rating Scale for Depression (HAM-D). We chose this outcome measure to have an estimate of the actual difference in effect sizes between treatments.
2. The relative risk (RR) of being a responder (more than 50 percent improvement from baseline) on the HAM-D or the Montgomery-Åsberg Depression Rating Scale (MADRS) at study endpoint.
3. The RR of achieving remission on the HAM-D or MADRS at study endpoint. The HAM-D definition for the 17-item version was ≤ 8, and for the 21-item version was ≤ 10. For the MADRS, the remission definition was a score of ≤ 8. If a study used a slightly different definition for remission, this difference was noted in the study's summary table and was included if, in the authors' judgment, it did not substantially differ from the above.

For each meta-analysis, we conducted a test of heterogeneity (I^2^ index) and applied both a random and a fixed-effects model. We report the results from random effects models because, in all meta-analyses, the results from random and fixed effects models were very similar. If the RR was statistically significant, we calculated the number needed to treat (NNT) from the pooled RR or the pooled risk differences if variations in baseline risks were small.

We assessed publication bias using funnel plots and Kendell's tests. However, given the small number of component studies in our meta-analyses, these tests have low sensitivity to detect publication bias.

If meta-analyses were not possible but we deemed that an estimation of a treatment effect was of particular interest, we conducted descriptive statistics of the above-mentioned outcome measures. We calculated weighted means and 95 percent confidence intervals of changes on HAM-D or MADRS, and the percentages of responders and remitters for specific interventions or treatment strategies. The findings provide an estimate of the average, expected treatment effect for a specific intervention. Nevertheless, they have to be interpreted cautiously. Because of the lack of control groups, no general efficacy can be inferred from such results. Furthermore, the magnitude of treatment effects should not be compared across interventions.

## Peer Review

This CER received external peer review from the TEP members and individuals who were experts in fields relevant to TRD (listed in the front matter) and from various stakeholder and user communities. The SRC managed the peer review process. If reviewers provided additional references to consider for inclusion in the final report, we reviewed all suggested references and included those that were appropriate and within the scope of this CER. We also addressed all comments and revised the report accordingly.