# Discussion

## Background

This review from the RTI International-University of North Carolina at Chapel Hill Evidence-based Practice Center provides a comprehensive summary of the available data addressing the comparative effectiveness of four nonpharmacologic treatments— electroconvulsive therapy (ECT), repetitive transcranial magnetic stimulation (rTMS), vagus nerve stimulation (VNS), and cognitive behavioral therapy (CBT) or interpersonal psychotherapy —as therapies for patients with treatment-resistant depression (TRD). For one issue (see key questions [KQs] below), we also examined pharmacologic (antidepressant) interventions. The core patient population of interest was patients with major depressive disorder (MDD) who met our definition of TRD: failure to respond following two or more adequate antidepressant trials. We also included studies in which the patient population could include a “mix” of up to 20 percent of patients with bipolar disorder (i.e., 80 percent or more of patients had only MDD), assuming that this small mix would not substantially alter outcomes seen with MDD-only populations. In addition, we distinguished between patients for whom treatment was directed at the acute phase of disease and those for whom treatment was intended to maintain remission or to prevent relapse.

We structured our review to focus chiefly on our primary population of interest (MDD patients with TRD) but also considered data from studies that likely had a substantial proportion of TRD patients. We worked with our Technical Expert Panel to identify different tiers of definitions for TRD to use in our analytic strategy:

- Tier 1 evidence (TRD as defined in this report): studies in which patients specifically had two or more prior treatment failures with medications.
- Tier 2 evidence: studies in which patients had one or more prior treatment failures.
- Tier 3 evidence: studies in which the number of prior treatment failures was not specified but the clinical situation suggested a high probability of patients having two or more prior antidepressant treatment failures; this data has probable relevance to TRD. Studies which did not specify the number of failed treatments but noted that all subjects were referred for ECT were included in this tier.

The focus of each of the six KQs or subquestions is listed below (key distinguished elements in italics).

- KQ 1a. Efficacy of nonpharmacologic interventions for acute-phase TRD (depressive severity, response, or remission).
- KQ 1b. Efficacy of nonpharmacologic versus pharmacologic interventions for acute-phase TRD (depressive severity, response, or remission), for patients with two or more prior treatment failures.
- KQ 2. Efficacy of nonpharmacologic interventions for maintaining response or remission with respect to TRD (e.g., preventing relapse or recurrence).
- KQ 3. Efficacy of nonpharmacologic interventions for acute-phase TRD as a function of particular symptom subtypes (e.g., catatonia or psychosis).
- KQ 4. Harms of nonpharmacologic interventions (i.e., safety, adverse events, or adherence issues).
- KQ 5. Efficacy or harms of nonpharmacologic treatments for selected patient subgroups defined by sociodemographic characteristics or coexisting conditions.
- KQ 6. Health-related outcomes of nonpharmacologic treatments (e.g., quality of life).

In the discussion below, we comment on findings from direct and indirect evidence for clearly defined TRD (Tier 1); where differences were clinically meaningful, we provide the data also reported in Results. Respectively, these terms refer to head-to-head studies or studies involving a control group of some sort, such as a sham procedure or usual care (treatment as usual). As with Results, we include only studies for which we rated the quality as either good or fair; most studies were of only fair quality.

Finally, we graded the strength of evidence for major outcomes and comparisons for the clearly defined TRD population (Tier 1). Detailed information for data from all three tiers was presented in Results, and the reader can refer to the detailed analysis sections in Results for evidence involving Tier 2 and Tier 3 studies. Below, we comment in text about the strength of evidence for the main findings specifically for TRD. To recap, the four levels of strength of evidence are as follows:

1. High: High confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
2. Moderate: Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
3. Low: Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and is likely to change the estimate.
4. Insufficient: Evidence either is unavailable or does not permit estimation of an effect.

## Overview of Main Findings

Summaries of our main findings are found in Table 97 through Table 106. If a specific comparison did not involve a Tier 1 population but did have trials conducted in a Tier 2 and/or Tier 3 population, we have listed it in this table, noted “No eligible studies identified,” and added a footnote indicating the presence of at least one such study.

Table 97 Summary of findings on nonpharmacologic treatment of adult treatment-resistant depression (TRD) with strength of evidence for Tier 1 (TRD) for Key Question 1a. comparative efficacy of nonpharmacologic treatments

Comparison | Outcome | Number of Subjects | Strength of Evidence^*^ | Findings^†^
ECT vs. rTMS | Change in depressive severity | 42 | Low | 1 fair trial: both ECT and rTMS improved symptom severity but did not differ significantly.
ECT vs. rTMS | Response rate | 42 | Low | 1 fair trial: ECT and rTMS did not differ significantly.
ECT vs. rTMS | Remission rate | 42 | Low | 1 fair trial: ECT and rTMS did not differ significantly.
ECT plus rTMS vs. ECT | Change in depressive severity | 22 | Low | 1 fair trial: both ECT and ECT plus rTMS improved symptom severity but did not differ significantly.
ECT plus rTMS vs. ECT | Response rate | 0 | NA | No eligible studies identified. ‡
ECT plus rTMS vs. ECT | Remission rate | 22 | ow | 1 fair trial: ECT and ECT plus rTMS did not differ significantly.
ECT vs. sham | Change in depressive severity | 0 | NA | No eligible studies identified. ‡
ECT vs. sham | Response rate | 0 | NA | No eligible studies identified. ‡
ECT vs. sham | Remission rate | 0 | NA | No eligible studies identified. ‡
rTMS vs. sham | Change in depressive severity | 497 | High | 7 trials (3 good, 4 fair): rTMS had a significantly greater decrease in depressive severity than sham. 4 fair trials: rTMS had nonsignificantly greater decrease in depressive severity than sham. 2 fair trials: rTMS had greater decrease than sham but significance NR. 1 fair trial: rTMS did not significantly differ from sham.
rTMS vs. sham | Response rate | 471 | High | 4 trials (3 good, 1 fair): rTMS had a significantly higher response rate than sham. 1 fair trial: rTMS had a nonsignificantly higher response rate than sham. 6 fair trials: rTMS had a higher response rate than sham, but significance NR. 1 fair trial: rTMS did not clearly differ from sham, but significance NR.
rTMS vs. sham | Remission rate | 223 | Moderate | 3 trials (2 good, 1 fair): rTMS had significantly greater remission rate than sham. 2 fair trials: rTMS had a greater remission rate than sham but significance NR.
VNS vs. sham | Change in depressive severity | 235 | Low | 1 good trial: VNS and sham did not differ significantly.
VNS vs. sham | Response rate | 235 | Low | 1 good trial: VNS and sham did not differ significantly.
Psychotherapy vs. control | Change in depressive severity | 0 | NA | No eligible studies identified. ‡
Psychotherapy vs. control | Response rate | 0 | NA | No eligible studies identified. ‡
Psychotherapy vs. control | Remission rate | 0 | NA | No eligible studies identified. ‡

ECT = electroconvulsive therapy; NA = not applicable; NR = not reported; rTMS = repetitive transcranial magnetic stimulation; VNS = vagus nerve stimulation; vs. = versus

* Strength of evidence is based on the EPC program's modified version of the GRADE system; see text.

† Good and fair designations relate to quality ratings for each study.

‡ At least one Tier 2 or Tier 3 study addressed this comparison.

Table 98 Summary of findings on nonpharmacologic treatment of adult treatment-resistant depression (TRD) with strength of evidence for Tier 1 (TRD) for KQ 1b. comparative efficacy of nonpharmacologic and pharmacologic treatments

Comparison | Outcome | Number of Subjects | Strength of Evidence^*^ | Findings^†^
ECT vs. pharmacotherapy | Change in depressive severity | 39 | Low | 1 fair trial: ECT had significantly greater improvement in symptom severity than pharmacotherapy.
ECT vs. pharmacotherapy | Response rate | 39 | Low | 1 fair trial: ECT had significantly greater response rates than pharmacotherapy.
Psychotherapy vs. pharmacotherapy | Change in depressive severity | 0 | NA | No eligible studies identified. ‡
Psychotherapy vs. pharmacotherapy | Response rate | 0 | NA | No eligible studies identified. ‡
Psychotherapy vs. pharmacotherapy | Remission rate | 0 | NA | No eligible studies identified. ‡

ECT = electroconvulsive therapy; NA = not applicable; rTMS = repetitive transcranial magnetic stimulation; vs. = versus

* Strength of evidence is based on guidance provided in the AHRQ Methods Guide for Comparative Effectiveness Reviews; see text.

† Good and fair designations relate to quality ratings for each study.

‡ At least one Tier 2 and/or Tier 3 study addressed this comparison.

Table 99 Summary of findings on nonpharmacologic treatment of adult treatment-resistant depression (TRD) with strength of evidence for Tier 1 (TRD) for KQ 2. comparative efficacy for maintaining remission

Comparison | Outcome | Number of Subjects | Strength of Evidence^*^ | Findings^†^
ECT vs. rTMS | Maintenance of remission | 0 | NA | No eligible studies identified. ‡
rTMS vs. sham | Maintenance of remission | 68 | Insufficient | 3 fair trials: no significant differences in maintenance of remission however, small sample sizes in two of the studies and the presence of a co-intervention in the third study make results difficult to interpret
CBT vs. usual care | Maintenance of remission | 0 | NA | No eligible studies identified. ‡

CBT = cognitive behavioral therapy; ECT = electroconvulsive therapy; NA = not applicable; rTMS = repetitive transcranial magnetic stimulation; vs. = versus

* Strength of evidence is based on guidance provided in the AHRQ Methods Guide for Comparative Effectiveness Reviews system; see text.

† Good and fair designations relate to quality ratings for each study.

‡ At least one Tier 2 and/or Tier 3 study addressed this comparison.

Table 100 Summary of findings on nonpharmacologic treatment of adult treatment-resistant depression (TRD) with strength of evidence for Tier 1 (TRD) for KQ 3. comparative efficacy for particular symptom subtypes

Comparison | Outcome | Number of Subjects | Strength of Evidence^*^ | Findings^†^
ECT vs. rTMS | Change in depressive severity | 0 | NA | No eligible studies identified. ‡

ECT = electroconvulsive therapy; NA = not applicable; rTMS = repetitive transcranial magnetic stimulation; vs. = versus

* Strength of evidence is based on guidance provided in the AHRQ Methods Guide for Comparative Effectiveness Reviews; see text.

† Good and fair designations relate to quality ratings for each study.

‡ At least one Tier 2 and/or Tier 3 study addressed this comparison.

Table 101 Summary of findings on nonpharmacologic treatment of adult treatment-resistant depression (TRD) with strength of evidence for Tier 1 (TRD) for KQ 4a. impact of nonpharmacologic interventions on cognitive functioning

Comparison | Outcome | Number of Subjects | Strength of Evidence^*^ | Findings^†^
ECT vs. rTMS | Cognitive functioning | 72 | Insufficient | 1 fair trial and 1 fair cohort study: Some evidence suggests no difference between treatments, whereas some evidence suggests ECT may have deleterious impact on cognitive functioning compared with rTMS (1 study: significant effect on 1-week recall; both studies: nonsignificant effect on all other measures).
ECT vs. ECT + rTMS | Cognitive functioning | 22 | Insufficient | 1 fair trial: no significant differences in a single item measure on memory problems
rTMS vs. sham | Cognitive functioning | 101 | Insufficient | 3 trials (1 good, 2 fair): Some evidence suggests no difference between rTMS and sham, whereas some evidence suggests that rTMS improves cognitive functioning compared to sham (2 trials: significant differences in memory, verbal fluency; all other findings nonsignificant or significance not reported)

ECT = electroconvulsive therapy; rTMS = repetitive transcranial magnetic stimulation; vs. = versus

* Strength of evidence is based on guidance provided in the AHRQ Methods Guide for Comparative Effectiveness Reviews; see text.

† Good and fair designations relate to quality ratings for each study.

Table 102 Summary of findings on nonpharmacologic treatment of adult treatment-resistant depression (TRD) with strength of evidence for Tier 1 (TRD) for KQ 4b. specific adverse events

Comparison | Outcome | Number of Subjects | Strength of Evidence^*^ | Findings^†^
ECT vs. rTMS | Adverse events | 0 | NA | No eligible studies identified. ‡
ECT vs. ECT + rTMS | Adverse events | 22 | Low | 1 fair trial: no significant differences in specific adverse events
rTMS vs. sham | Adverse events | 68 | Low | 1 good trial: rTMS resulted in significantly more scalp pain at the stimulation site than sham.
VNS vs. sham | Adverse events | 235 | Low | 1 fair trial: Some differences in specific adverse events reported (P = NR)

ECT = electroconvulsive therapy; NA = not applicable; rTMS = repetitive transcranial magnetic stimulation; VNS = vagus nerve stimulation; vs. = versus

* Strength of evidence is based on guidance provided in the AHRQ Methods Guide for Comparative Effectiveness Reviews; see text.

† Good and fair designations relate to quality ratings for each study.

‡ At least one Tier 2 and/or Tier 3 study addressed this comparison.

Table 103 Summary of findings on nonpharmacologic treatment of adult treatment-resistant depression (TRD) with strength of evidence for Tier 1 (TRD) for KQ 4c. withdrawals due to adverse event

Comparison | Outcome | Number of Subjects | Strength of Evidence^*^ | Findings^†^
ECT vs. rTMS | Withdrawals | 30 | Low | 1 fair cohort study: no difference in withdrawals between ECT and rTMS groups (P = NR).
ECT vs. sham | Withdrawals | 0 | NA | No eligible studies identified. ‡
rTMS vs. sham | Withdrawals | 277 | Insufficient | 7 trials (1 good, 6 fair): trials showed mixed results about withdrawals attributed to adverse events.
VNS vs. sham | Withdrawals | 235 | Low | 1 good trial: VNS had greater withdrawals attributed to adverse events than sham (significance NR).
CBT vs. usual care | Withdrawals | 0 | NA | No eligible studies identified. ‡

CBT = cognitive behavioral therapy; ECT = electroconvulsive therapy; NA = not applicable; NR = not reported; rTMS = repetitive transcranial magnetic stimulation; VNS = vagus nerve stimulation; vs. = versus

* Strength of evidence is based on guidance provided in the AHRQ Methods Guide for Comparative Effectiveness Reviews; see text.

† Good and fair designations relate to quality ratings for each study.

‡ At least one Tier 2 and/or Tier 3 study addressed this comparison.

Table 104 Summary of findings on nonpharmacologic treatment of adult treatment-resistant depression (TRD) with strength of evidence for Tier 1 (TRD) for KQ 4d. adherence as measured by overall withdrawals

Comparison | Outcome | Number of Subjects | Strength of Evidence^*^ | Findings^†^
ECT vs. rTMS | Overall withdrawals | 72 | Low | 1 fair trial and 1 fair cohort study: studies showed more withdrawals in ECT group compared with sham (P = NR).
ECT vs. sham | Overall withdrawals | 0 | NA | No eligible studies identified. ‡
rTMS vs. sham | Overall withdrawals | 325 | Insufficient | 8 fair trials: trials showed mixed results about withdrawals.
CBT vs. usual care | Overall withdrawals | 0 | NA | No eligible studies identified. ‡

CBT = cognitive behavioral therapy; ECT = electroconvulsive therapy; NA = not applicable; rTMS = repetitive transcranial magnetic stimulation; vs. = versus

* Strength of evidence is based guidance provided in the AHRQ Methods Guide for Comparative Effectiveness Reviews; see text.

† Good and fair designations relate to quality ratings for each study.

‡ At least one Tier 2 and/or Tier 3 study addressed this comparison.

Table 105 Summary of findings on nonpharmacologic treatment of adult treatment-resistant depression (TRD) with strength of evidence for Tier 1 (TRD) for KQ 5. efficacy and harms for selected populations

Comparison | Outcome | Number of Subjects | Strength of Evidence^*^ | Findings^†^
rTMS vs. sham | Changes in depressive severity | 34 | Low | 1 fair trial: rTMS produced better outcome than sham in young adult population (ages 18–37).
rTMS vs. sham | Changes in depressive severity | 20 | Low | 1 fair trial: rTMS produced better outcome than sham in older adults with post-stroke depression.
rTMS vs. sham | Response | 34 | Low | 1 fair trial: rTMS produces better response rates than sham in young adult population (ages 18–37).
rTMS vs. sham | Response | 20 | Low | 1 fair trial: no difference between rTMS and sham for older adults with post-stroke depression.
rTMS vs. sham | Remission | 20 | Low | 1 fair trial: no difference between rTMS and sham in older adults with post-stroke depression.

rTMS = repetitive transcranial magnetic stimulation; vs. = versus

* Strength of evidence is based on guidance provided in the AHRQ Methods Guide for Comparative Effectiveness Reviews; see text.

† Good and fair designations relate to quality ratings for each study.

Table 106 Summary of findings on nonpharmacologic treatment of adult treatment-resistant depression (TRD) with strength of evidence for Tier 1 (TRD) for KQ 6. health-related outcomes

Comparison | Outcome | Number of Subjects | Strength of Evidence^*^ | Findings^†^
ECT vs. ECT + rTMS | Health-related outcomes | 22 | Low | There were no differences between groups in improvements in daily functioning.
rTMS vs. sham | Health-related outcomes | 60 | Low | 1 fair trail: low rTMS had significantly greater improvement in health status and daily functioning than sham, while this relationship approached statistical significance when comparing high rTMS to sham.
VNS vs. sham | Health-related outcomes | 214 | Low | 1 fair trial: VNS and sham groups did not differ significantly in daily functioning.
CBT/DBT vs. control | Health-related outcomes | 0 | NA | No eligible studies identified. ‡

CBT = cognitive behavioral therapy; DBT = dialectical behavioral therapy; NA = not applicable; rTMS = repetitive transcranial magnetic stimulation; VNS = vagus nerve stimulation; vs. = versus

* Strength of evidence is based on guidance provided in the AHRQ Methods Guide for Comparative Effectiveness Reviews; see text.

† Good and fair designations relate to quality ratings for each study.

‡ At least one Tier 2 and/or Tier 3 study addressed this comparison.

### KQ 1a Efficacy of Acute-Phase Interventions: Nonpharmacologic Interventions Against Each Other in TRD Populations (Tier 1)

#### Direct Evidence

The available head-to-head literature concerning the efficacy of the nonpharmacologic interventions for Tier 1 TRD is limited to two fair trials (both in MDD-only populations) (Table 107). One compared ECT and rTMS, and the other compared ECT and ECT plus rTMS. They showed, with low strength of evidence, no differences between treatment options for depressive severity, response rates, and remission rates. No trial involved a direct comparison of VNS or psychotherapy with another nonpharmacologic intervention.

Table 107 Number of Tier 1 (TRD) studies of head-to-head comparisons of nonpharmacologic treatments, by comparison

Comparison | Number
ECT plus rTMS vs. ECT | 1
ECT vs. rTMS | 1

ECT = electroconvulsive therapy; rTMS = repetitive transcranial magnetic stimulation

#### Indirect Evidence

We identified trials that compared a nonpharmacologic intervention, generally rTMS, VNS, or psychotherapy, with a control or sham procedure in Tier 1 populations. We identified no eligible ECT versus control studies (Table 108). The number of these trials with the same or similar control group was very small, so we could not pool them quantitatively. We could, however, assess the potential benefits of nonpharmacologic interventions versus controls by calculating mean changes in depressive severity, relative risks of response, and relative risks of remission.

Table 108 Number of Tier 1 (TRD) studies of nonpharmacologic interventions against controls or usual care, by comparison

Intervention and Control | Number
ECT vs. sham | 0
rTMS vs. sham procedure | 15
VNS plus usual care vs. usual care | 1
Psychotherapy plus usual care vs. usual care | 0

ECT = electroconvulsive therapy; rTMS = repetitive transcranial magnetic stimulation; VNS = vagus nerve stimulation; vs. = versus

rTMS was beneficial relative to controls receiving a sham procedure for all three outcomes (severity of depressive symptoms, response rate, remission rate). rTMS produced a greater decrease in depressive severity (high strength of evidence). Specifically, rTMS averaged a decrease in depressive severity measured by the Hamilton Rating Scale for Depression (HAM-D) of more than 5 points relative to sham control, and this change meets the minimum threshold of the 3-point HAM-D difference that is considered clinically meaningful. Response rates were greater with rTMS than sham (also high strength of evidence); those receiving rTMS were more than 3 times as likely to achieve a depressive response as patients receiving a sham procedure. Finally, rTMS was also more likely to produce remission than the control procedure (moderate strength of evidence); patients receiving rTMS were more than 6 times as likely to achieve remission as those receiving the sham.

In the only other Tier 1 comparison, one good-quality VNS versus sham control trial (a mixed MDD/bipolar population) reported no differences between the groups as measured by a change in depressive severity or response rates (low strength of evidence).

### KQ 1b Efficacy of Acute-Phase Interventions: Nonpharmacologic Interventions Against Medications in TRD Populations (Tier 1)

#### Direct Evidence

The available head-to-head literature concerning the efficacy of the nonpharmacologic interventions compared with pharmacologic treatment (in this case, paroxetine) for Tier 1 trials is limited to one fair trial (a mixed MDD/bipolar population). ECT produced a significantly greater decrease in depressive severity (9 points by HAM-D) and significantly better response rates (71% vs. 28%) than medications (low strength of evidence) (Table 109).

Table 109 Number of Tier 1 (TRD) studies involving pharmacotherapy, by comparison

Intervention | Number
ECT vs. pharmacotherapy | 1
CBT vs. pharmacotherapy | 0

CBT = cognitive behavioral therapy; ECT = electroconvulsive therapy; vs. = versus

#### Indirect Evidence

Indirect evidence about procedures or psychotherapy (vs. sham or nonpharmacological controls) were presented above as part of KQ 1.

We attempted to determine mean changes in depressive severity, relative risks of response, and relative risks of remission for pharmacologic versus control studies to allow a comparison with similar outcomes in the nonpharmacologic versus control trials (KQ 1a, indirect). However, there were no comparable, common control groups not receiving a mood-related medication to allow such comparisons.

Instead, we determined mean average outcomes for pharmacologic treatments.

- For switching strategies, mean pharmacologic response rates averaged 39.8 percent (95% CI, 30.7–48.9) and mean remission rates averaged 22.3 percent (95% CI, 16.2–28.4);
- For augmentation, mean response rates averaged 38.1 percent (95% CI, 31.0–45.3) and mean remission rates average 27.2 percent (95% CI, 20.4–34.0); and
- For maintenance strategies, mean response rates averaged 27.3 percent (95% CI, 19.8–34.8) and mean remission rates averaged 16.8 percent (95% CI, 13.5–20.2).

Although these results provide an idea of the general degree of response seen with next-step pharmacologic treatment in TRD, they serve as an uncontrolled case series and should only be compared to nonpharmacologic outcomes with caution.

### KQ 2 Efficacy of Nonpharmacologic Interventions for Maintenance of Remission or Prevention of Relapse in TRD Populations (Tier 1)

#### Direct Evidence

With respect to maintaining remission (or preventing relapse), there were no direct comparisons involving ECT, rTMS, VNS, or CBT.

#### Indirect Evidence

Three fair trials compared rTMS with a sham procedure and found no significant differences, however, too few patients were followed during the relapse prevention phases in two of the three studies and patients in the third received a co-intervention providing insufficient evidence for a conclusion. We had no eligible studies for ECT, VNS, or psychotherapy.

### KQ 3 Efficacy of Nonpharmacologic Interventions for Patients with Different Symptomatology in TRD Populations (Tier 1)

#### Direct Evidence

We identified no Tier 1 trials that addressed whether procedure-based treatments differed as a function of symptom subtypes. Also, no comparative evidence was available about psychotherapy in subgroups defined by symptom clusters.

#### Indirect Evidence

We identified no studies testing either procedure-based or psychotherapeutic interventions against sham procedures or other controls.

### KQ 4 Harms of Nonpharmacologic Interventions in TRD Populations (Tier 1)

#### Direct Evidence

In examining safety, adverse events, and adherence, we found some differences across the interventions in the harms and negative side effects to patients, however the data were insufficient to reach a conclusive result. For just this set of analyses, we examined both trials and cohort studies, and we focus on cognitive functioning, occurrence of specific adverse events, and withdrawals.

##### Cognitive Functioning

For Tier 1 studies on cognitive functioning, some evidence suggests no differences in changes in cognitive functioning between groups, while some evidence suggests ECT may have a deleterious impact on cognitive functioning compared to rTMS (insufficient strength of evidence).

No differences between groups on a single item measure of cognitive functioning were found in a study comparing ECT with ECT and rTMS (insufficient strength of evidence).

##### Specific Adverse Events

One Tier 1 study comparing ECT with a combination of ECT and rTMS found no differences in specific adverse events (low strength of evidence).

##### Withdrawals

We looked at both withdrawals that investigators attributed to adverse events and overall numbers or rates of withdrawals. A single study with a small sample size indicated no difference in withdrawals due to adverse events for the ECT group when compared to rTMS but did not report on the significance of this result (low strength of evidence).

Evidence for ECT compared with rTMS indicated higher rates of overall withdrawals in the ECT compared to the rTMS group (P = NR; low strength of evidence).

#### Indirect Evidence

We attempted to include data from the same types of studies and for the same outcomes as for direct evidence. We identified no studies comparing ECT versus control.

##### Cognitive Functioning

Mixed evidence on cognitive functioning in rTMS versus sham was insufficient to draw a conclusion (insufficient strength of evidence).

##### Specific Adverse Events

rTMS groups reported significantly more scalp pain at the stimulation site (low strength of evidence).

Some differences in the frequency of specific adverse events were seen when comparing VNS and sham groups, but the significance of the findings was not reported (low strength of evidence).

##### Withdrawals

Findings were mixed in Tier 1 studies as to whether rTMS groups had greater rates of withdrawals due to adverse events and overall withdrawals than groups receiving sham procedures (insufficient evidence for both).

There was low strength of evidence that there were greater withdrawals due to adverse events in the vagus nerve stimulation group compared to sham.

No Tier 1 studies reported on withdrawals for CBT groups versus those receiving some form of usual care.

### KQ 5 Efficacy or Harms of Nonpharmacologic Treatments for Selected Patient Subgroups in TRD Populations (Tier 1)

#### Direct Evidence

We found no studies (in any tier) directly comparing nonpharmacologic interventions in selected populations, such as the elderly, those with stroke, or those with other medical comorbidities.

#### Indirect Evidence

Three Tier 1 trials compared rTMS versus sham. A single trial, each, found that rTMs produced a greater decrease in depressive severity than sham for young adults (ages 18–37) and in older adults with post-stroke depression (both low strength of evidence). A single trial in young adults indicated that rTMS produces a greater response rate than sham in young adults (ages 18–37) (low strength of evidence), while a single study identified no difference in response rates between rTMS and sham in older adults with post-stroke depression (low strength of evidence). Finally, a single study found no difference in remission rates for rTMS versus sham in older adults with post-stroke depression.

### KQ 6 Health-Related Outcomes of Nonpharmacologic Treatments in TRD Populations (Tier 1)

#### Direct Evidence

With respect to patient-reported health-related outcomes, we focused on quality of life (various measures) and ability to function in daily life. One Tier 1 study compared ECT with a combination of ECT and rTMS and found no differences between groups in improvement on the Global Assessment of Functioning scale (low strength of evidence).

#### Indirect Evidence

Two trials (both in mixed MDD/bipolar populations) assessed general health status and mental and physical functioning (all health domains related to quality of life). In one fair trial, low rTMS had significantly greater improvement in health status and daily functioning than sham, while this relationship approached statistical significance when comparing high rTMS to sham (as measured by the Global Assessment of Functioning scale; low strength of evidence). In the other fair trial, VNS and sham groups did not differ significantly in daily functioning (as measured by the 36-item Medical Outcomes Study Short Form [MOS SF-36]; low strength of evidence). No studies of psychotherapy were identified.

## Applicability

For the limited amount and low strength of evidence available, the data for Tier 1 (TRD) is generally applicable to TRD populations. Populations enrolled in these trials appeared representative of our target population. Studied interventions were comparable to those in routine use, though dose and duration of nonpharmacologic treatment often varied between studies. Measured outcomes on the whole reflected the most important clinical outcomes for depression measures, although reporting was inconsistent; outcomes for the other key questions were much more restricted. Followup periods were generally shorter than desirable, but most were sufficient to measure an initial acute-phase treatment response. Study settings were a mixture of inpatient and outpatient. Some evidence highlights the importance of patient acceptability of treatment as some patients refuse particular interventions. An individualized balance between patient's needs and concerns must be taken into account during selection from a range of nonpharmacologic and pharmacologic antidepressant treatment options. The use of varying definitions of TRD in the trials and the absence of analyses considering the effect of the number of current episode treatment failures on outcomes hindered interpretation of data, leading to the use of a tiered system. The evidence base combining data for Tiers 1–3 on the whole produced findings that were consistent with Tier 1 TRD data and also appear applicable to TRD populations.

### Limitations of the Evidence Base

#### Lack of use of a Standard Definition of TRD

Comparison of any of the potential interventions in the field, nonpharmacologic or otherwise, is hampered by variable definitions of TRD. Although these definitions appear to be consolidating towards a single meaning—two or more treatment failures in the current episode— very few studies of TRD have applied it. Use of multiple definitions makes synthesis of the available information difficult, as the effect of combining patients with one treatment failure with those of two or more (or four or more) remains unclear.

Similarly, the failure of studies to describe the number of treatment failures prevented us from being able to stratify our outcomes by the number of failed trials within Tier 1 studies and assess the role of number of failures in TRD on outcomes.

Ultimately, TRD is a complex phenomenon that encompasses the number of treatment failures, the adequacy of prior treatments, depressive severity, comorbidities (both psychiatric and medical), symptom subtypes, and chronicity. The currently available evidence base has yet to successfully and consistently apply a standard definition.

#### Failure to Consistently Assess Number of Failures in Current Episode

Given the difficulty in accurately assessing adequacy of prior treatment trials over a lifetime, a history of failed treatment attempts in a current episode is likely a more accurate measure of treatment resistance. It is likely that many of those who reported lifetime histories of two or more failures did have them in the current episode, but few studies required such a failure in their selection criteria; many studies may be mixing current failure with more chronic failures.

#### Few Head-to-Head Studies of Nonpharmacologic Intervention

The small number of existing head-to-head studies limits the strength of all our findings to either low or insufficient evidence, making firm conclusions about comparative effectiveness impossible. Only two studies occurred in our main population of interest: patients with MDD who had two or more antidepressant failures.58,64

#### Heterogeneity of the Populations (MDD and MDD/Bipolar mix)

This mixture of diagnostic disorders in samples made interpretation of the data difficult. Populations studied included MDD and MDD/bipolar mix patients. We selected a 20 percent cutoff to decrease the likelihood of the mix affecting outcomes (e.g., in a study of 40 patients, if 8 had bipolar disorder and were roughly evenly distributed between treatment arms, their outcomes would need to be extreme to substantially affect outcome). This need to clarify a specific cutoff, however, excluded studies that may have had relevant populations. Further, because results were not stratified by MDD and bipolar disease, the precision of the effect on the nonpharmacologic outcomes may have been distorted.

#### Failure to Consider a Spectrum of Depressive Severity

Most patients involved in studies were severely depressed and analyses did not assess how the degree of depression along the severity spectrum may affect outcomes in comparative studies. For example, the most severely depressed may have different outcomes with one versus another intervention than those who are severely depressed but to a lesser degree.

#### Heterogeneity of Interventions and Intervention Strategies

The literature is characterized by a large variety of treatment strategies used (augmentation, switch, a combination of the two), a wide variety of treatment parameters used (length and dose of ECT, number of rTMS sessions), and variable and uncontrolled use of psychotropic medications, all of which make interpretation and synthesis of the studies difficult.

Limited outcome elements assessed. Although they reported one or two of the pertinent outcomes, the majority of the relevant studies did not assess both response and remission rates. These measures are especially important to allow a clinically meaningful interpretation of findings.

#### Few Comparisons of Nonpharmacologic to Pharmacologic Treatments in TRD Patients

For many clinicians, the next step following failure of two antidepressant treatments is not consideration of a nonpharmacologic treatment but usually consideration of a different pharmacologic strategy. The role of nonpharmacologic interventions in the sequence of treatment choices remains unclear.

#### Difficulty in Identifying a Reasonable Sham Control Group for Device-Related Studies

Challenges in finding an appropriate sham arm may have distorted results from the intervention-control comparisons. Because of the need for general anesthesia, “sham ECT” has proven ethically problematic over the years. Given the noninvasive nature of rTMS, there is much objection to the use of a sham control condition, in which the electrode would be placed against the scalp but the magnetic stimulation not applied. The problem is that a completely “inert” sham condition experience may not be credible to patients who are aware of the noise and vibration that typically accompanies active rTMS.53,139 Similarly, the limited number of reported VNS studies identified have come under similar criticism for the apparently transparent nature of the control condition.140

#### Inadequate Study Design to Assess Longer Term Outcomes

Studies need to have more long-term monitoring over time so that the outcomes can be further studied. For example, the available studies for ECT did not follow patients long enough to assess potential cumulative effects on cognitive functioning that may distinguish it from other interventions. Additionally, longer monitoring periods are necessary to compare the maintenance of remission.

#### Studies Were not Designed to Answer Many of the Outcomes Relevant to the KQ

Outcomes such as relapse, cognitive functioning, adverse events, withdrawal due to adverse events, and health-related outcomes are not often primary outcomes, limiting the power to adequately test hypotheses about such differences between nonpharmacologic interventions.

#### Absence of Psychotherapy Studies Involving a TRD Population

Although some Tier 2 and 3 studies involved psychotherapy, there were no studies addressing a Tier 1 population (TRD). Also, no studies from any tiers involved interpersonal therapy. While there are a variety of reasons that make clinical trials involving psychotherapy challenging (e.g., treatments are often not widely available outside research centers, and both patients and clinicians often view these studies as underpowered or the research protocol as too complicated for application in practice settings), such research would be quite informative for decisionmakers.

#### These Treatments are Quite Different

Differences in these interventions—how long it takes to reach an adequate dose, how effectively patients can be blinded, how long it takes to obtain a response, how long the results last—make it challenging to directly compare these varying treatments. For example, with ECT, if there is no effect in 2 weeks, one might consider switching treatments, whereas with CBT, such a latency would not be a cause for concern.

## Limitations of This Review

This area of comparative clinical research is in its infancy, and few relevant trials were available. The paucity of data limited our ability to pool findings statistically. Specifically, we were not able to quantitatively synthesize data from head-to-head comparisons, nor were we able to indirectly compare the nonpharmacologic literature by pooling data from studies sharing equivalent control groups. Our synthesis, then, is primarily qualitative.

The dearth of relevant trials also prevented us from assessing whether key elements might suggest one nonpharmacologic treatment over another. In particular, we were unable to assess what the effect on outcome was of key, clinically relevant elements of interest: population variables (MDD and MDD/bipolar mix; varying depressive severity; and requiring treatment failures to be in the current episode) and intervention variables (using an augmentation versus switch treatment strategy; varying by nonpharmacologic treatment characteristics).

## Future Research

This area of comparative clinical research is in its infancy. Key areas for future research need primarily to lay more robust foundations for an evidence base that can better inform decisions for clinicians and patients.

### The Field Needs a Standard Definition of TRD That Investigators Should use in Their Clinical Trials Research

Comparison of any of the potential interventions in the field, nonpharmacologic or otherwise, is hampered by the variability in TRD definitions. Although these definitions appear to be converging on a single meaning—two or more treatment failures in the current episode—very few studies of TRD have applied it. Progress in this area of research requires better standardization of this concept, so that future reviews of the evidence do not need to resort to differentiating, as we did, between “Tier 1” studies (i.e., TRD by this definition based on two or more treatment failures) and “Tier 2 or 3” types of studies. The latter do provide information that helps illuminate likely impacts of these interventions on patients with TRD, but that is not the same thing as having robust studies focused clearly on the patient population of greatest interest. The challenge will be to provide a definition that operationalizes TRD to make it feasible for clinicians while at the same time successfully capturing the complexity of treatment resistance.

### More Clinical Trials, as Well as Other Possible Study Designs, That Compare Nonpharmacologic Interventions With Other Nonpharmacologic Options and With Pharmacologic Treatments are Necessary to Inform Decisionmaking in TRD

Clinicians, patients, and policymakers need additional relevant data to guide difficult treatment decisions about what to do next: try another medication trial (and should it be an augmentation, switch, or combination strategy?); add (or switch to) rTMS, ECT, VNS, or psychotherapy?

Also, given that treatment options for many TRD patients include medications, trials should directly compare nonpharmacologic interventions with each other and with pharmacologic treatments.

### The Number of Treatment Failures in the Current Episode Should be Delineated Carefully

This information, more likely to be accurate than lifetime histories of failures, can help investigators determine whether the particular number of failures, or reaching a particular number of failures in a current episode, can help differentiate between nonpharmacologic treatment choices. For example, for patients with two failures in a current episode, the outcomes may not differ between cognitive therapy and rTMS; however, for patients with a different (higher or lower) number of failures in the current episode, one nonpharmacologic treatment may indeed be better than the other. Currently, we do not know what the proper threshold is for selection of treatment. Clarification of the scientific basis for such a decision would substantially improve decisionmaking.

### Clarifying Whether Responses Differ for TRD Patients With MDD Compared to Those With Bipolar Disorder Will Help to Guide Future Clinical Trial Design

Our decision to include trials with patient populations including up to 20 percent with bipolar disorder (i.e., the “mixed” populations noted earlier) was guided by clinical experience and common sense but not by data. Testing to see whether outcomes differ between the two groups can yield information about inclusion criteria (should the mix be 0%, 10%, 20%, etc.?) that may be useful to investigators in designing TRD trials and may be important to consider as a potential covariate in analyses involving such mixes.

### Greater Consideration Should be Given to the Role That the Spectrum of Depressive Severity Plays

Using a finer gradation of depressive severity than investigators now typically employ might identify whether particularly severe degrees of depression, most commonly understood currently as a HAM-D_17_ ≥ 20, may respond differently to the available nonpharmacologic interventions than do less severe levels of depression. These gradations may lead clinicians to a better understanding of severe depression and its role in guiding treatment selection in TRD.

### Direct Comparisons of Treatment Strategies, Holding Consistent any Coexisting or Concomitant Therapies, are Imperative

Decisionmakers need to know whether outcomes with nonpharmacologic treatments are better when such a treatment augments the current treatment, replaces the current treatment, or replaces the current treatment in combination with another treatment. When ongoing treatment is uncontrolled and reflects a variety of treatments—e.g., some patients continue with atypical antipsychotics, some with mood stabilizers, some with no psychotropic medications—results of such studies are difficult, if not impossible, to interpret.

### Consistent Reporting of Changes in Depressive Severity, Response Rates, and Remission Rates is Crucial

To allow for better comparisons of clinical outcomes in this difficult-to-treat population, all three measures offer useful information for clinicians. Thus, for either trials or observational studies, investigators should attempt to collect data on all three routinely.

### Application of Consistent, Accepted Protocols in Trials is Necessary

Making sure that patients receive equivalent doses of different nonpharmacologic interventions is more difficult than making sure of this for pharmacologic interventions. Nevertheless, investigators designing trials of nonpharmacologic therapies can attempt to do so by implementing standard accepted protocols for their trials. Such “dosing” had been difficult to control when that protocol was in the process of being developed, as with rTMS, but given current treatment parameters, this standardization is a goal well worth trying to reach.

### More Careful and Consistent Assessment of Adverse Events is Required

Adverse event reporting is quite limited and over a short timespan, and what exists is variable and inconsistent. Systematic collection and more consistent reporting of data on harms—i.e., adverse events and negative side effects—and information about attrition and withdrawal would provide useful information to help balance information now focused on clinical benefits. Use of the CONSORT (Consolidated Standards of Reporting Trials) statement (available at: http://www.consort-statement.org/home/), which guides proper reporting of study information (including the presentation of adverse events), would strengthen reporting both harms and other clinical trial findings; it would also aid in the critical appraisal and interpretation of all study results. Further, a more informative assessment of adverse events would require studies to be able to assess long-term and cumulative outcomes.

### Including key Relevant Measures and Subgroups in Subsequent Research is Desirable

As indicated by the review, nearly no evidence exists on how the effectiveness of nonpharmacologic treatments differs (or not) as a function of symptom subtypes or for subgroups defined by sociodemographic characteristic (such as age) or coexisting medical conditions (e.g., post-stroke or postmyocardial infarction depression; perinatal depression). Also essentially missing is information about health-related outcomes, especially those reported by patients, that concern their quality of life or levels of functional impairment. Subsequent studies should focus on employing known, reliable, and valid measures of patient-reported outcomes, such as the MOS SF-36,^141^ the Quality of Life Enjoyment and Satisfaction Questionnaire (Q-LES-Q),135 and the EQ-5D.142

### Including Comparisons of Newer Nonpharmacologic Interventions Will be Important in Future Research

As new nonpharmacologic treatments are developed and tested, investigators should try to include them as potential comparators. At the time we started this comparative effectiveness review, clinical trial data on some of the developing nonpharmacologic interventions, such as magnetic seizure therapy,143-145 deep brain stimulation,146-148 or mindfulness-based cognitive therapy149 were insufficient (from the published literature) for us to try to include them. As the evidence bases grow to support the efficacy of such additional nonpharmacologic interventions, the newer strategies should be included in comparative effectiveness study designs.

## Conclusion

Our review suggests that comparative clinical research on nonpharmacologic interventions in a TRD population is in its infancy, and many clinical questions about efficacy and effectiveness remain unanswered. Interpretation of the data is substantially hindered by varying definitions of TRD and the paucity of relevant studies. The greatest volume of evidence is for ECT and rTMS; however, even for the few comparisons of treatments that are supported by some evidence, the strength of evidence is low for comparative benefits. Specifically, there was low strength of evidence that ECT and rTMS did not produce different clinical outcomes in TRD, and low strength of evidence that ECT produced better outcomes than pharmacotherapy. No trials directly compared the likelihood of maintaining remission for nonpharmacologic interventions. The few trials addressing adverse events, subpopulations, subtypes, and health-related outcomes provided low or insufficient evidence of differences between nonpharmacologic interventions. The most urgent next steps for research are to apply a consistent definition of TRD, to conduct more head-to-head clinical trials comparing nonpharmacologic interventions to one another and to pharmacologic treatments, and to carefully delineate the number of adequate treatment failures in the current episode.