# Studies Recommended for Inclusion by Peer and Public Reviewers

1 American Psychiatric Association Committee on Electroconvulsive T, Weiner RD. The practice of electroconvulsive therapy: a task force report of the American Psychiatric Association. Washington, D.C. American Psychiatric Association. Rationale: This reference is a set of guidelines. Guidelines do not fit the inclusion criteria for appropriate publication types. The guidelines were not included in the analysis of this review.
2 Avery DH, Isenberg KE, Sampson SM, et al. Transcranial magnetic stimulation in the acute treatment of major depressive disorder: clinical response in an open-label extension trial. J Clin Psychiatry. Mar. 2008;69(3):441-51. [pmid: 18294022]. Rationale: This reference was excluded due to a lack of comparison of interventions between groups. All patients participating in the open-label study receive the same intervention.
3 Bajbouj M, Merkl A, Schlaepfer TE, et al. Two-year outcome of vagus nerve stimulation in treatment-resistant depression. Journal of Clinical Psychopharmacology. June. 2010;30(3):273-81. [pmid: 20473062]. Rationale: This reference was excluded for the present analysis due to a lack of comparison of interventions. The study analyzes outcome measures after 3, 12, and 24 months of vagal nerve stimulation.
4 Berman RM, Narasimhan M, Sanacora G, et al. A randomized clinical trial of repetitive transcranial magnetic stimulation in the treatment of major depression. Biological Psychiatry. Feb. 2000;47(4):332-7. [pmid: 10686268]. Rationale: This study in included in the present analysis
5 Clinical Psychiatry Committee. Clinical trial of the treatment of depressive illness: Report to the Medical Research Council. Br Med J. 1965;1:881-886. [pmid: 14257398]. Rationale: This reference is from prior to the start date of our search criteria and it is not of a TRD population
6 Demitrack MA, Loo CK, Maixner DF, et al. Transcranial Magnetic Stimuatlin (TMS) in the Treatment of Pharmacoresistant Major Depression: Examination of Cognitive Function During Acute Treatment. Society for Biological Psychiatry Annual Meeting New Research Sessions of the American Psychiatric Association Annual Meeting. Vancouver B.C. San Francisco, CA. 2009. Rationale: This conference proceeding was included in our analysis as a companion article to O'Reardon, 2007.^1^
7 Demitrack MA, Thase ME. Clinical significance of transcranial magnetic stimulation (TMS) in the treatment of pharmacoresistant depression: synthesis of recent data. Psychopharmacol Bull. July. 2009;42(2):5-38. [pmid: 19629020]. Rationale: This article was excluded due to the wrong publication type. The study pooled two studies for the analysis. The current review reviewed both studies pooled for analysis for inclusion in this report. One article, O'Reardon, 2007^1^ was included in our analysis. The second article, Avery, 2008^2^ was excluded due to no comparison of interventions (see number 2 above).
8 Fava M, Rush AJ, Wisniewski SR, et al. A comparison of mirtazapine and nortriptyline following two consecutive failed medication treatments for depressed outpatients: a STAR*D report. Am J Psychiatry. 2006:1161-72. Rationale: This study was included in the Key Question 1b analysis (pharmaceutical interventions). Because it is comparing to pharmaceutical interventions it was only eligible to be included in Key Question 1.
9 George MS, Lisanby SH, Avery D, et al. Daily left prefrontal transcranial magnetic stimulation therapy for major depressive disorder: a sham-controlled randomized trial. Arch Gen Psychiatry. May. 2010;67(5):507-16. [pmid: 20439832]. Rationale: This study was included in the current analysis.
10 George MS, Rush AJ, Marangell LB, et al. A one-year comparison of vagus nerve stimulation with treatment as usual for treatment-resistant depression. Biol Psychiatry. Sep. 1. 2005;58(5):364-73. [pmid: 16139582]. Rationale: This study was excluded from Key Question 2 (maintenance of response) analysis due to wrong study design (observational study). The protocol for this review states that only randomized controlled trials and meta-analyses are eligible study designs for this key question.
11 Hausmann A, Pascual-Leone A, Kemmler G, Rupp CI, Lechner-Schoner T, Kramer-Reinstadler K, et al. No deterioration of cognitive performance in an aggressive unilateral and bilateral antidepressant rTMS add-on trial. Journal of Clinical Psychiatry. Jun. 2004;65(6):772-82. [pmid: 15291654]. Rationale: This study was excluded from analysis as it is not apparent that the population is treatment resistant. The article does not refer to the population as resistant or refractory, nor does it discuss prior treatment failures of the included population.
12 Janicak PG, Nahas Z, Lisanby SH, et al. Durability of clinical benefit with transcranial magnetic stimulation (TMS) in the treatment of pharmacoresistant major depression: Assessment of relapse during a 6-month, multisite, open-label study, Brain Stimulation. Netherlands. Elsevier Science. 2010:187-99. Rationale: This article is included in the present analysis.
13 Janicak PG, O'Reardon JP, Sampson SM, et al. Transcranial magnetic stimulation in the treatment of major depressive disorder: a comprehensive summary of safety experience from acute exposure, extended exposure, and during reintroduction treatment. J Clin Psychiatry. 2008:222-32. Rationale: This article is included in the present analysis.
14 Janicak PG, Nahas Z, Lisanby SH, et al. Durability of acute tesponse to TMS in the treatment of major depression: relapse during a continuation pharmacotherapy extension study, Society for Biological Psychiatry Annual Meeting. 2007. May. San Diego, CA. Rationale: This article is included in the present analysis.
15 Kellner CH, Knapp RG, Petrides G, et al. Continuation electroconvulsive therapy vs pharmacotherapy for relapse prevention in major depression: a multisite study from the Consortium for Research in Electroconvulsive Therapy (CORE). Arch Gen Psychiatry. 2006:1337-44. Rationale: This study was excluded for not meeting criteria for a treatment resistant population. The article states that only 42.7 percent of a portion of the population rated (using the ATHF) as having had at least one adequate failure. This indicates that 57.3 percent of this population did not have at least one treatment failure. The entire population, therefore, cannot be considered treatment-resistant by this review's definition.
16 Kozel FA, George MS, Simpson KN. Decision Analysis of Cost-Effectiveness of Repetitive Transcranial Magnetic Stimulation Versus Electroconvulsive Therapy for Treatment of Nonpsychotic Severe Depression. CNS Spectrums. Jun. 2004;9(6):476-82. [pmid: 15162090]. Rationale: This study was excluded from the current analysis due to reporting outcomes that are not of interest for this review. The study reports on an economic decision analysis.
17 Leichsenring F, Rabung S. Effectiveness of long-term psychodynamic psychotherapy: a meta-analysis. JAMA. Oct. 1. 2008;300(13):1551-65. [pmid: 18827212]. Rationale: This meta-analysis was not included in the current analysis due to inclusion of the wrong population. It could not be determined that the included populations met the criteria of treatment-resistant depression.
18 Lisanby SH, Husain MM, Rosenquist PB, et al. Daily left prefrontal repetitive transcranial magnetic stimulation in the acute treatment of major depression: clinical predictors of outcome in a multisite, randomized controlled clinical trial. Neuropsychopharmacology. Jan. 2009;34(2):522-34. [pmid: 18704101]. Rationale: This study was excluded for wrong outcome. The study attempts to determine predictors of outcomes which is not an outcome of interest for this review.
19 Lisanby SH, Maddox JH, Prudic J, et al. The effects of electroconvulsive therapy on memory of autobiographical and public events. Arch Gen Psychiatry. Jun. 2000;57(6):581-90. [pmid: 10839336]. Rationale: This study was excluded from the analysis. The study performs its analysis on right unilateral compared to bilateral electrode placement for electroconvulsive therapy. It also compares low versus high electrical dosage. Neither of these comparisons are comparisons of interest for this review.
20 Martis B, Alam D, Dowd SM, et al. Neurocognitive effects of repetitive transcranial magnetic stimulation in severe major depression. Clin Neurophysiol. Jun. 2003;114(6):1125-32. [pmid: 12804681]. Rationale: This article was excluded from this review due to no comparison. This article, although part of a larger randomized controlled trial, only reports on those persons receiving rTMS. The study does not report on any comparison intervention.
21 Nahas Z, Marangell LB, Husain MM, et al. Two-year outcome of vagus nerve stimulation (VNS) for treatment of major depressive episodes. J Clin Psychiatry. Sep. 2005;66(9):1097-104. [pmid: 16187765]. Rationale: This article was excluded from this review due to no comparison. This study analyzes the outcomes from patients treated with vagal nerve stimulation. No other intervention is compared.
22 Nelson AL, Cohen JT, Greenberg D, et al. Much cheaper, almost as good: decrementally cost-effective medical innovation. Ann Intern Med. Nov. 3. 2009;151(9):662-7. [pmid: 19884627]. Rationale: This meta-analysis was excluded from the current analysis for wrong outcomes. The meta-analysis reviews cost-utility analyses which are not outcomes of interest for the current review.
23 Nemeroff CB, Heim CM, Thase ME, et al. Differential responses to psychotherapy versus pharmacotherapy in patients with chronic forms of major depression and childhood trauma. Proc Natl Acad Sci USA. Nov. 25. 2003;100(24):14293-6. [pmid: 14615578]. Rationale: This study was excluded from the current analysis for including the wrong population. The identical sample used in this study was taken from Keller, 2000 3 which was excluded from the current review due to wrong population. The population of the parent study and this subsequent study used as exclusion criteria “absence of a response to three previous adequate trials of at least two different classes of antidepressants or electroconvulsive therapy or to two previous adequate trials of empirical psychotherapy in the three years preceding the study; a serious, unstable medical condition; or a positive urine screen for drugs of abuse. Furthermore, out of the entire study population, 19.7 percent had received no prior treatment for depression.
24 Nierenberg AA, Fava M, Trivedi MH, et al. Comparison of Lithium and T3 Augmentation Following Two Failed Medication Treatments for Depression: A STAR*D Report. The American Journal of Psychiatry. Sept. 2006;163(9):1519-30. [pmid: 16946176]. Rationale: This study was excluded from the current analysis do to wrong intervention. T3 is not an augmenter of interest for Key Question 1b (pharmaceutical) analysis.
25 O'Reardon JP, Solvason HB, Janicak PG, et al. Efficacy and safety of transcranial magnetic stimulation in the acute treatment of major depression: a multisite randomized controlled trial. Biol Psychiatry. 2007:1208-16. Rationale: This study is included in the current analysis. It is not included for Key Question 3 (symptom subtypes). Symptom subtypes represented by standard factor scores measured on the Hamilton Depression Rating Scale are not symptom subtypes of interest for this report.
26 Rossi S, Hallett M, Rossini PM, Pascual-Leone A. Safety, ethical considerations, and application guidelines for the use of transcranial magnetic stimulation in clinical practice and research. Clin Neurophysiol. Dec. 2009;120(12):2008-39. [pmid: 19833552]. Rationale: This study was not included in the current analysis because it does not represent a publication type of interest. The reference is cited within the text of the current review.
27 Rumi DO, Gattaz WF, Rigonatti SP, et al. Transcranial magnetic stimulation accelerates the antidepressant effect of amitriptyline in severe depression: a double-blind placebo-controlled study. Biol Psychiatry. Jan. 15. 2005;57(2):162-6. [pmid: 15652875]. Rationale: This study was not included in the current analysis due to inclusion of wrong population. The study makes no reference to the population as resistant or refractory, nor does it address prior treatment failure.
28 Rush AJ, Marangell LB, Sackeim HA, et al. Vagus nerve stimulation for treatment-resistant depression: a randomized, controlled acute phase trial. Biological Psychiatry. Sep. 2005. 2005;58(5):347-54. [pmid: 16139580]. Rationale: This study in included in the current analysis.
29 Rush AJ, Trivedi MH, Wisniewski SR, et al. Bupropion-SR, sertraline, or venlafaxine-XR after failure of SSRIs for depression. N Engl J Med. Mar. 23. 2006;354(12):1231-42. [pmid: 16554525]. Rationale: This study was not included for Key Question 1b (Pharmaceutical analysis) because the population did not meet the criteria of 2 or more treatment failures. Key Question 1b required included populations to have 2 or more treatment failures.
30 Sackeim HA, Haskett RF, Mulsant BH, et al. Continuation pharmacotherapy in the prevention of relapse following electroconvulsive therapy: a randomized controlled trial. JAMA. Mar. 14. 2001;285(10):1299-307. [pmid: 11255384]. Rationale: This study was not included for Key Question 1b (pharmaceutical analysis) because the population did not meet the criteria of 2 or more treatment failures. Key Question 1b required included populations to have 2 or more treatment failures.
31 Sackeim HA, Brannan SK, Rush AJ, et al. Durability of antidepressant response to vagus nerve stimulation (VNS). Int J Neuropsychopharmacol. Dec. 2007;10(6):817-26. [pmid: 17288644]. Rationale: This study was not included in the current analysis because it does not contain a comparison of interest. The study analyzes outcomes after vagal nerve stimulation and compares outcomes between responders and non-responders.
32 Sackeim HA, Prudic J, Devanand DP, et al. A prospective, randomized, double-blind comparison of bilateral and right unilateral electroconvulsive therapy at different stimulus intensities. Arch Gen Psychiatry. 2000;57(5):425-34. [pmid: 10807482]. Rationale: This study was not included in the current analysis because the analysis does not include a comparison of interest. The study compares right unilateral ECT at three different thresholds to bilateral ECT at one threshold. There is no other intervention comparison.
33 Sackeim HA, Prudic J, Fuller R, et al. The cognitive effects of electroconvulsive therapy in community settings. Neuropsychopharmacology. Jan. 2007;32(1):244-54. [pmid: 16936712]. Rationale: This study was not included in the current analysis because the analysis does not include a comparison. The study compares baseline and post-treatment outcomes after electroconvulsive therapy.
34 Simpson KN, Welch MJ, Kozel FA, et al. Cost-effectiveness of transcranial magnetic stimulation in the treatment of major depression: a health economics analysis. Adv Ther. Mar. 2009;26(3):346-68. [pmid: 19330495]. Rationale: This study was not included in the current analysis for reporting outcomes that were not of interest for the current review. The study performs cost-effective analyses. Please note the study is cited in the text of the review.
35 Tew JD Jr, Mulsant BH, Haskett RF, et al. Relapse during continuation pharmacotherapy after acute response to ECT: a comparison of usual care versus protocolized treatment. Ann Clin Psychiatry. Jan-Mar. 2007;19(1):1-4. [pmid: 17453654]. Rationale: This study was excluded for wrong comparison. In this continuation study which would have been considered for key question 2, the study only compares pharmacotherapy to treatment as usual which is not a comparison of interest for this key question.
36 Thase ME, Friedman ES, Biggs MM, et al. Cognitive therapy versus medication in augmentation and switch strategies as second-step treatments: a STAR*D report. Am J Psychiatry. 2007:739-52. Rationale: This study is included in the current analysis.
37 Trivedi MH, Fava M, Wisniewski SR, et al. Medication augmentation after the failure of SSRIs for depression. N Engl J Med. Mar. 23. 2006;354(12):1243-52. [pmid: 16554526]. Rationale: This study was excluded for wrong population. This study population did not meet the strict population criteria of Key Question 1b which required the entire population to have failed at least 2 prior treatments.
38 Williams N, Simpson AN, Simpson K, et al. Relapse rates with long-term antidepressant drug therapy: a meta-analysis. Hum Psychopharmacol. July. 2009;24(5):401-8. [pmid: 19526453]. Rationale: This meta-analysis was not included in this review because it included populations that are not treatment-resistant. The authors clearly stated that three of the studies excluded treatment-resistant depression and seven studies had no criteria pertaining to TRD.
39 Efficacy and safety of electroconvulsive therapy in depressive disorders: a systematic review and meta-analysis. Lancet. Mar. 8. 2003;361(9360):799-808. [pmid: 12642045]. Rationale: Overall review excluded because populations were not all TRD, but we note that two of the studies from this SER are included in KQ1a.

## References

1 O'Reardon JP, Solvason HB, Janicak PG, et al. Efficacy and safety of transcranial magnetic stimulation in the acute treatment of major depression: a multisite randomized controlled trial. Biol Psychiatry. 2007:1208-16.
2 Avery DH, Isenberg KE, Sampson SM, et al. Transcranial magnetic stimulation in the acute treatment of major depressive disorder: clinical response in an open-label extension trial. J Clin Psychiatry. Mar. 2008;69(3):441-51. [pmid: 18294022].
3 Keller MB, McCullough JP, Klein DN, et al. A comparison of nefazodone, the cognitive behavioral-analysis system of psychotherapy, and their combination for the treatment of chronic depression. N Engl J Med. 2000;342(20):1462-70. [pmid: 10816183].