# Articles by Database Searched

## Cochrane Database = 82 articles (excluding duplicates)

1 Abbass Allan A, Hancock Jeffrey T, Henderson J, Kisely Steve R. Short-term psychodynamic psychotherapies for common mental disorders, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2006.
2 Akechi T, Okuyama T, Onishi J, Morita T, Furukawa Toshi A. Psychotherapy for depression among incurable cancer patients, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2008.
3 Algul A, Sen H, Ates MA, Yen T, Durmaz O, Ozkan S, et al. Propofol versus propofol-remifentanil combination anaesthesia in electroconvulsive therapy: effects on seizure duration and hemodynamics. Klinik Psikofarmakoloji Bulteni. 2009:24-8.
4 Bausewein C, Booth S, Gysels M, Higginson Irene J. Non-pharmacological interventions for breathlessness in advanced stages of malignant and non-malignant diseases, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2008.
5 Bisson J, Andrew M. Psychological treatment of post-traumatic stress disorder (PTSD), Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2007.
6 BlueCross BlueShield A. Transcranial magnetic stimulation for depression (Structured abstract). Chicago IL. Blue Cross Blue Shield Association (BCBS): Blue Cross Blue Shield Association (BCBS). 2009.
7 Brent D, Melhem N, Ferrell R, Emslie G, Wagner KD, Ryan N, et al. Association of FKBP5 polymorphisms with suicidal events in the Treatment of Resistant Depression in Adolescents (TORDIA) study. The American Journal of Psychiatry. 2010:190-7.
8 Bschor T, Baethge C. No evidence for switching the antidepressant: systematic review and meta-analysis of RCTs of a common therapeutic strategy (Provisional abstract). Acta Psychiatrica Scandinavica. 2010:174-9.
9 Burgess Sally SA, Geddes J, Hawton Keith KE, Taylor Matthew J, Townsend E, Jamison K, et al. Lithium for maintenance treatment of mood disorders, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2001.
10 Caldwell D, Hunot V, Moore Theresa HM, Davies P, Jones H, Lewis G, et al. Behavioural therapies versus treatment as usual for depression, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
11 Callahan P, Hetrick Sarah E, Churchill R, Hunot V, Merry Sally N, Parker Alexandra G. Psychological therapies versus antidepressant medication, alone and in combination for depression in children and adolescents, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
12 Christmas David MB, Crombie I, Eljamel S, Fineberg N, MacVicar B, Matthews K, et al. Neurosurgery for obsessive-compulsive disorder, other anxiety disorders and depressive disorders, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2005.
13 Churchill R, Caldwell D, Moore Theresa HM, Davies P, Jones H, Lewis G, et al. Behavioural therapies versus other psychological therapies for depression, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
14 Churchill R, Davies P, Caldwell D, Moore Theresa HM, Jones H, Lewis G, et al. Humanistic therapies versus other psychological therapies for depression, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
15 Churchill R, Davies P, Caldwell D, Moore Theresa HM, Jones H, Lewis G, et al. Interpersonal, cognitive analytic and other integrative therapies versus treatment as usual for depression, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
16 Churchill R, Hunot V, Corney R, Knapp M, McGuire H, Tylee A, et al. Brief cognitive-behavioural therapies versus other brief psychological therapies for depression. Cochrane Database of Systematic Reviews. 2007;(2).
17 Churchill R, Hunot V, Corney R, Knapp M, McGuire H, Tylee A, et al. Brief psychological therapies versus treatment as usual for depression. Cochrane Database of Systematic Reviews. 2007;(2).
18 Churchill R, Moore Theresa HM, Caldwell D, Davies P, Jones H, Furukawa Toshi A, et al. Cognitive behavioural therapies versus other psychological therapies for depression, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
19 Churchill R, Moore Theresa HM, Davies P, Caldwell D, Jones H, Lewis G, et al. Psychodynamic therapies versus other psychological therapies for depression, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
20 Churchill R, Moore Theresa HM, Davies P, Caldwell D, Jones H, Lewis G, et al. Mindfulness-based ‘third wave’ cognitive and behavioural therapies versus treatment as usual for depression, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
21 Claudino Angélica M, Hay Phillipa PJ, Silva de Lima M, Schmidt Ulrike US, Bacaltchuk J, Treasure J. Antipsychotic drugs for anorexia nervosa, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2007.
22 Davies P, Hunot V, Moore Theresa HM, Caldwell D, Jones H, Lewis G, et al. Humanistic therapies versus treatment as usual for depression, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
23 Duehmke Rudolf M, Hollingshead J, Cornblath David R. Tramadol for neuropathic pain, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2006.
24 Gibbon S, Duggan C, Stoffers J, Huband N, Völlm Birgit A, Ferriter M, et al. Psychological interventions for antisocial personality disorder, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
25 Gregory RJ, DeLucia-Deranja E, Mogle JA. Dynamic deconstructive psychotherapy versus optimized community care for borderline personality disorder co-occurring with alcohol use disorders: a 30-month follow-up. The Journal of nervous and mental disease. 2010:292-8.
26 Gupta A, Durham R. Cognitive behavioural therapy (CBT) for adults with HIV, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2007.
27 Hay Phillipa PJ, Bacaltchuk J, Byrnes Roanna T, Claudino Angélica M, Ekmejian Avedis A, Yong Poh Y. Individual psychotherapy in the outpatient treatment of adults with anorexia nervosa, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2003.
28 He L, Guo J, Zhou M, Yang M, Zhu C. Repetitive transcranial magnetic stimulation for the treatment of amyotrophic lateral sclerosis or motor neuron disease, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
29 Herrmann LL, Ebmeier KP. Factors modifying the efficacy of transcranial magnetic stimulation in the treatment of depression: a review (Structured abstract). Journal of Clinical Psychiatry. 2006;(12):1870-6. [pmid: 17194264].
30 Hilton Malcolm P, Stuart Emma L. Ginkgo biloba for tinnitus, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2004.
31 Hoffbrand Sara E, Howard L, Crawley H. Antidepressant treatment for post-natal depression, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2001.
32 Hunot V, Moore Theresa HM, Caldwell D, Davies P, Jones H, Furukawa Toshi A, et al. Cognitive behavioural therapies versus treatment as usual for depression, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
33 Hunot V, Moore Theresa HM, Caldwell D, Davies P, Jones H, Lewis G, et al. Interpersonal, cognitive analytic and other integrative therapies versus other psychological therapies for depression, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
34 Hunot V, Moore Theresa HM, Caldwell D, Davies P, Jones H, Lewis G, et al. Mindfulness-based ‘third wave’ cognitive and behavioural therapies versus other psychological therapies for depression, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
35 Ipser Jonathan C, Carey P, Dhansay Y, Fakier N, Seedat S, Stein Dan J. Pharmacotherapy augmentation strategies in treatment-resistant anxiety disorders, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2006.
36 Ipser Jonathan C, Pillay Nirvana S, Stein Dan J, van Honk J. Transcranial magnetic stimulation for post-traumatic stress disorder, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2007.
37 Ipser Jonathan C, Sander C, Stein Dan J. Pharmacotherapy and psychotherapy for body dysmorphic disorder, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2009.
38 Ipser Jonathan C, Stein Dan J. Newer anticonvulsants in the treatment of anxiety disorders, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2006.
39 Ipser Jonathan C, Stein Dan J, Hawkridge S, Hoppe L. Pharmacotherapy for anxiety disorders in children and adolescents, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2009.
40 Jackson Kenneth C, Lipman Arthur G. Drug therapy for anxiety in adult palliative care patients, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2004.
41 Jayaram Mahesh B, Hosalli P, Stroup TS. Risperidone versus olanzapine for schizophrenia, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2006.
42 Jones C, Cormac I, Silveira da Mota Neto Joaquim I, Campbell C. Cognitive behaviour therapy for schizophrenia, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2004.
43 Justo L, Soares Bernardo Garcia de O, Calil H. Family interventions for bipolar disorder, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2007.
44 Kang JI, Kim CH, Namkoong K, Lee CI, Kim SJ. A randomized controlled study of sequentially applied repetitive transcranial magnetic stimulation in obsessive-compulsive disorder. The Journal of clinical psychiatry. 2009:1645-51.
45 Komossa K, Depping Anna M, Kissling W, Leucht S. Second-generation antipsychotic drugs for obsessive compulsive disorder, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2009.
46 Leucht S, Kissling W, McGrath J. Lithium for schizophrenia, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2007.
47 Leucht S, Kissling W, McGrath J, White P. Carbamazepine for schizophrenia, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2007.
48 Li Y, Zeng Rui F, Zheng D. Acupuncture for tinnitus, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2009.
49 Liu X, Zhang M, He L, Li Y. Chinese herbs combined with Western medicine for severe acute respiratory syndrome (SARS), Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2006.
50 Maneeton N, Srisurapanont M. Tricyclic antidepressants for depressive disorders in children and adolescents: a meta-analysis of randomized-controlled trials (Structured abstract). Journal of the Medical Association of Thailand. 2000:1367-74.
51 Marques Luciana de O, Soares B, Silva de Lima M. Trifluoperazine for schizophrenia, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2004.
52 Moore Theresa HM, Hunot V, Davies P, Caldwell D, Jones H, Lewis G, et al. Psychodynamic therapies versus treatment as usual for depression, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
53 Nelson JC, Papakostas GI. Atypical antipsychotic augmentation in major depressive disorder: a meta-analysis of placebo-controlled randomized trials (Structured abstract). American Journal of Psychiatry. 2009:980-91.
54 O'Connell Neil E, Wand Benedict M, Marston L, Spencer S, DeSouza Lorraine H. Non-invasive brain stimulation techniques for chronic pain, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
55 Oude Voshaar Richard C, Hendriks GJ, Keijsers G, van Balkom Anton J. Cognitive behavioural therapy for anxiety disorders in later life, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2009.
56 Papakostas GI, Mischoulon D, Shyu I, Alpert JE, Fava M. S-adenosyl methionine (SAMe) augmentation of serotonin reuptake inhibitors for antidepressant nonresponders with major depressive disorder: a double-blind, randomized clinical trial. The American journal of psychiatry. 2010:942-8.
57 Ramaratnam S, Baker Gus A, Goldstein Laura H. Psychological treatments for epilepsy, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2008.
58 Rodriguez-Martin José L, Barbanoj José M, Schlaepfer TE, Clos Susana SC, Pérez V, Kulisevsky J, et al. Transcranial magnetic stimulation for treating depression, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2001.
59 Roxburgh C, Cook J, Dublin N. Anticholinergic drugs versus other medications for overactive bladder syndrome in adults, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2007.
60 Saarto T, Wiffen Philip J. Antidepressants for neuropathic pain, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2007.
61 Schwarz C, Hartung B, Leucht S. Benperidol for schizophrenia, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2005.
62 Seitz Dallas P, Adunuri N, Gill S, Gruneir A, Herrmann N, Rochon P. Antidepressants for agitation and psychosis in dementia, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
63 Shek E, Bardhan S, Cheine Maxim V, Ahonen J, Wahlbeck K. Beta-blocker supplementation of standard drug treatment for schizophrenia, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2001.
64 Shek E, Stein Airton T, Shansis Flavio M, Marshall M, Crowther R, Tyrer P. Day hospital versus outpatient care for people with schizophrenia, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2009.
65 Stein Dan J, Ipser Jonathan C, Seedat S. Pharmacotherapy for post traumatic stress disorder (PTSD), Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2006.
66 Stein Dan J, Ipser Jonathan C, van Balkom Anton J. Pharmacotherapy for social anxiety disorder, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2000.
67 Tharyan P, Adams Clive E. Electroconvulsive therapy for schizophrenia, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2005.
68 Timmer A, Jantschek G, Moser G, Motschall E, Preiss Jan C, Rücker G. Psychological interventions for treatment of inflammatory bowel disease, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2008.
69 Tsoi Daniel T, Porwal M, Webster Angela C. Interventions for smoking cessation and reduction in individuals with schizophrenia, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2010.
70 Tuunainen A, Kripke Daniel F, Endo T. Light therapy for non-seasonal depression, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2004.
71 Uthman Olalekan A, Abdulmalik Jubril O. Adjunctive therapies for AIDS dementia complex, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2008.
72 Van Der Wurff FB, Stek ML, Hoogendijk WJ, Beekman AT. The efficacy and safety of ECT in depressed older adults: a literature review (Brief record). International Journal of Geriatric Psychiatry. 2003;(10):894-904. [pmid: 14533122].
73 Vasudev A, Macritchie K, Rao Sanjay NK, Geddes J, Young Allan H. Tiagabine in the maintenance treatment of bipolar disorders, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2006.
74 Vasudev A, Macritchie K, Rao Sanjay NK, Geddes J, Young Allan H. Tiagabine in the treatment of acute affective episodes in bipolar disorder, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2006.
75 Veronese A, Hunot V, Cipriani A, Churchill R, Barbui C. Psychological therapies versus pharmacotherapy for obsessive compulsive disorder, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2008.
76 Volz A, Khorsand V, Gillies D, Leucht S. Benzodiazepines for schizophrenia, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2007.
77 Whale R, Terao T, Cowen P, Freemantle N, Geddes J. Pindolol augmentation of serotonin reuptake inhibitors for the treatment of depressive disorder: a systematic review (Provisional abstract). Journal of Psychopharmacology. 2010:513-20.
78 Wiffen Philip J, Derry S, Moore RA, McQuay Henry J. Carbamazepine for acute and chronic pain in adults, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2005.
79 Wijkstra J, Lijmer J, Balk F, Geddes J, Nolen Willem A. Pharmacological treatment for psychotic depression, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2005.
80 Wilson K, Mottram PG, Vassilas C. Psychotherapeutic treatments for older depressed people. Cochrane Database of Systematic Reviews. 2008;(1).
81 Zakrzewska Joanna M, Forssell H, Glenny AM. Interventions for the treatment of burning mouth syndrome, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2005.

## EMBASE Database = 390 articles (excluding duplicates)

1 The new antidepressant agent venlafaxine is effective in therapy resistance. [German]. Fortschritte der Medizin. 1997;115(4).
2 Opinion and evidence in neurology and psychiatry. CNS Drugs. 2003;17(6):449-56.
3 Adli M, Bschor T, Bauer M, Lucka C, Lewitzka U, Ising M, et al. Long-term outcome after lithium augmentation in unipolar depression: Focus on HPA system activity. Neuropsychobiology. September. 2009;60(1):23-30. [pmid: 19684420].
4 Aizenstein HJ, Reynolds CF III. The treatment of geriatric depression: progress and challenges. Economics of Neuroscience. 2001;3(7):58-62.
5 Akcaboy ZN, Akcaboy EY, Yigitbasi B, Bayam G, Dikmen B, Gocus N, et al. Effects of remifentanil and alfentanil on seizure duration, stimulus amplitudes and recovery parameters during ECT. Acta Anaesthesiologica Scandinavica. 2005;49(8):1068-71. [pmid: 16095445].
6 Aklillu E, Karlsson S, Zachrisson OO, Ozdemir V, Agren H. Association of MAOA gene functional promoter polymorphism with CSF dopamine turnover and atypical depression. Pharmacogenetics and Genomics. April. 2009;19(4):267-75. [pmid: 19214141].
7 Albert U, Brunatto C. Obsessive-compulsive disorder in adults: Efficacy of combined and sequential treatments. Clinical Neuropsychiatry. 2009;6(2):83-93.
8 Allen LA, Woolfolk RL, Lehrer PM, Gara MA, Escobar JI. Cognitive behavior therapy for somatization disorder: A preliminary investigation. Journal of Behavior Therapy and Experimental Psychiatry. 2001;32(2):53-62. [pmid: 11764061].
9 Alonso P, Pujol J, Cardoner N, Benlloch L, Deus J, Menchon JM, et al. Right prefrontal repetitive transcranial magnetic stimulation in obsessive-compulsive disorder: A double-blind, placebo-controlled study. Am J Psychiatry. 2001;158(7):1143-5. [pmid: 11431238].
10 Ananth J, Wohl M, Ranganath V, Beshay M. Rapid cycling patients: Conceptual and etiological factors. Neuropsychobiology. 1993;27(4):193-8. [pmid: 8232838].
11 Anderson DN. Treating depression in old age: the reasons to be positive. Age and Ageing. 2001;30(1):13-7. [pmid: 11322666].
12 Anderson SW, Booker MB. Cognitive behavioral therapy versus psychosurgery for refractory obsessive-compulsive disorder [1]. Journal of Neuropsychiatry and Clinical Neurosciences. 2006;18(1):129. [pmid: 16525082].
13 Andersson G, Kaldo V. Internet-based cognitive behavioral therapy for tinnitus. J Clin Psychol. Feb. 2004;60(2):171-8. [pmid: 14724924].
14 Angelucci F, Ricci V, Martinotti G, Caltagirone C, Bria P. Paliperidone for treatment of obsessive compulsive resistant symptoms in schizophrenia: A case report. Progress in Neuro-Psychopharmacology and Biological Psychiatry. 01. Oct. 2009;33(7):1277-8. [pmid: 19555731].
15 Anttila S, Viikki M, Huuhka K, Huuhka M, Huhtala H, Rontu R, et al. TPH2 polymorphisms may modify clinical picture in treatment-resistant depression. Neuroscience Letters. 16. Oct. 2009;464(1):43-6. [pmid: 19679166].
16 Arya A, Singh M, Gurwara AK. A comparison of thiopentone sodium, propofol and midazolam for electroconvulsive therapy. Journal of Anaesthesiology Clinical Pharmacology. 2008;24(3):291-4.
17 Asaknow JR, Emslie G, Clarke G, Wagner KD, Spirito A, Vitiello B, et al. Treatment of selective serotonin reuptake inhibitor-resistant depression in adolescents: predictors and moderators of treatment response. J Am Acad Child Adolesc Psychiatry. 2009;48(3):330-9. [pmid: 19182688].
18 Auriacombe M, Grabot D, Lincheneau PM, Zeiter D, Tignol J. Use of midazolam for ECT anesthesia: effects on antidepressive efficacy and seizure duration. Preliminary findings. Eur Psychiatry. 1995;10(6):312-6. [pmid: 19698359].
19 Avramov MN, Stool LA, White PF, Husain MM. Effects of nicardipine and labetalol on the acute hemodynamic response to electroconvulsive therapy. Journal of Clinical Anesthesia. 1998;10(5):394-400. [pmid: 9702620].
20 Aydemir O, Deveci A, Taskin EO. Mirtazapine combination in treatment-resistant major depressive disorder: A retrospective evaluation of six weeks. Klinik Psikofarmakoloji Bulteni. 2009;19(4):347-52.
21 Aziz M, Mehringer AM, Mozurkewich E, Razik GN. Cost-utility of 2 maintenance treatments for older adults with depression who responded to a course of electroconvulsive therapy: Results from a decision analytic model. Can J Psychiatry. 2005;50(7):389-97. [pmid: 16086536].
22 Aziz R, Lorberg B, Tampi RR. Treatments for late-life bipolar disorder. Am J Geriatr Pharmacother. 2006;4(4):347-64. [pmid: 17296540].
23 Bachar E, Lerer B, Shapira B. Increment in reminiscing after ECT: possible connections to neuropsychologic changes [2]. J ECT. 1999;15(2):165-6. [pmid: 10378158].
24 Baeken C, De Raedt R, Leyman L, Schiettecatte J, Kaufman L, Poppe K, et al. The impact of one HF-rTMS session on mood and salivary cortisol in treatment resistant unipolar melancholic depressed patients. J Affect Disord. Feb. 2009;113(1-2):100-8. [pmid: 18571733].
25 Baeken C, De Raedt R, Santermans L, Zeeuws D, Vanderhasselt MA, Meers M, et al. HF-rTMS treatment decreases psychomotor retardation in medication-resistant melancholic depression. Progress in Neuro-Psychopharmacology and Biological Psychiatry. May. 2010;34(4):684-7. [pmid: 20307619].
26 Baeken C, De Raedt R, Vanderhasselt MA, Leyman L, Schiettecatte J, Poppe K, et al. A “hypersensitive” hypothalamic-pituitary-adrenal system could be indicative for a negative clinical high-frequency repetitive transcranial magnetic stimulation outcome in melancholic depressed patients. Brain Stimulation. 2010:54-7.
27 Bailine S, Fink M, Knapp R, Petrides G, Husain MM, Rasmussen K, et al. Electroconvulsive therapy is equally effective in unipolar and bipolar depression. Acta Psychiatrica Scandinavica. June. 2010;121(6):431-6. [pmid: 19895623].
28 Bajbouj M, Merkl A, Schlaepfer TE, Frick C, Zobel A, Maier W, et al. Two-year outcome of vagus nerve stimulation in treatment-resistant depression. Journal of Clinical Psychopharmacology. June. 2010;30(3):273-81. [pmid: 20473062].
29 Baldwin RC. Research into depressive disorder in later life: who is doing what? A literature search from 1998-2001. Int Psychogeriatr. 2002;14(4):335-46. [pmid: 12670056].
30 Barocka A, Flugel D. Treatment resistant depression. [German]. Nervenheilkunde. 1989;8(6):253-7.
31 Bauer J, Hageman I, Dam H, Baez A, Bolwig T, Roed J, et al. Comparison of propofol and thiopental as anesthetic agents for electroconvulsive therapy: A randomized, blinded comparison of seizure duration, stimulus charge, clinical effect, and cognitive side effects. Journal of ECT. June. 2009;25(2):85-90. [pmid: 19092676].
32 Bauer M. Absolutely therapy-resistant depression and mixed movement disorder in an unusual case of polycythemia vera. Pharmacopsychiatry. 1995;28(2):66-8. [pmid: 7624389].
33 Bauer M, Hellweg R, Baumgartner A. High dose thyroxine in patients with therapy- and prophylaxis-resistant affective disorders. [German]. Nervenarzt. 1998;69(11):1019-22. [pmid: 9859125].
34 Bauer MS. The collaborative practice model for bipolar disorder: design and implementation in a multi-site randomized controlled trial. Bipolar Disorders. 2001;3(5):233-44. [pmid: 11903206].
35 Bech P, Stokes PE, Greden JF, Tollefson GD. Acute therapy of depression. Journal of Clinical Psychiatry. 1993;54(8 SUPPL):18-27. [pmid: 8253702].
36 Benedetti F, Barbini B, Fulgosi MC, Colombo C, Dallaspezia S, Pontiggia A, et al. Combined total sleep deprivation and light therapy in the treatment of drug-resistant bipolar depression: Acute response and long-term remission rates. Journal of Clinical Psychiatry. 2005;66(12):1535-40. [pmid: 16401154].
37 Benitez-Rosario MA, McDarby G, Doyle R, Fabby C. Chronic Cluster-Like Headache Secondary to Prolactinoma: Uncommon Cephalalgia in Association with Brain Tumors. Journal of Pain and Symptom Management. February. 2009;37(2):271-6. [pmid: 18694630].
38 Bennett HA, Einarson A, Taddio A, Koren G, Einarson TR. Depression during pregnancy: Overview of clinical factors. Clin Drug Investig. 2004;24(3):157-79.
39 Birkenhager TK, Van Den Broek WW, Mulder PGH, De Lely A. One-year outcome of psychotic depression after successful electroconvulsive therapy. J ECT. 2005;21(4):221-6. [pmid: 16301881].
40 Bitonti AJ, Sjoerdsma A, McCann PP, Kyle DE, Oduola AMJ, Rossan RN, et al. Reversal of chloroquine resistance in malaria parasite Plasmodium falciparum by desipramine. Science. 1988;242(4883):1301-3. [pmid: 3057629].
41 Blatt SJ, Sanislow CA III, Zuroff DC, Pilkonis PA. Characteristics of effective therapists: further analyses of data from the National Institute of Mental Health Treatment of Depression Collaborative Research Program. J Consult Clin Psychol. 1996;64(6):1276-84. [pmid: 8991314].
42 Boggio PS, Rocha M, Oliveira MO, Fecteau S, Cohen RB, Campanha C, et al. Noninvasive brain stimulation with high-frequency and low-intensity repetitive transcranial magnetic stimulation treatment for posttraumatic stress disorder. Journal of Clinical Psychiatry. August. 2010;71(8):992-9. [pmid: 20051219].
43 Bozhuyuk E, Poyraz CA, Poyraz BC, Ozdemir A, Savrun BM, Arikan MK. Persistent hiccups with fluvoxamine: A case report. Yeni Symposium. 2009;47(4):161-3.
44 Braslow JT, Duan N, Starks SL, Polo A, Bromley E, Wells KB. Generalizability of studies on mental health treatment and outcomes, 1981 to 1996. Psychiatr Serv. 2005;56(10):1261-8. [pmid: 16215192].
45 Brosse AL, Sheets ES, Lett HS, Blumenthal JA. Exercise and the treatment of clinical depression in adults: Recent findings and future directions. Sports Med. 2002;32(12):741-60. [pmid: 12238939].
46 Calabrese JR, Vieta E, El-Mallakh R, Findling RL, Youngstrom EA, Elhaj O, et al. Mood state at study entry as predictor of the polarity of relapse in bipolar disorder. Biol Psychiatry. 2004;56(12):957-63. [pmid: 15601606].
47 Calvert NW, Burch SP, Fu AZ, Reeves P, Thompson TR. The cost-effectiveness of lamotrigine in the maintenance treatment of adults with bipolar I disorder. J Manag Care Pharm. 2006;12(4):322-30. [pmid: 16792438].
48 Cassano GB, Jori MC. Efficacy and safety of amisulpride 50 mg versus paroxetine 20 mg in major depression: A randomized, double-blind, parallel group study. International Clinical Psychopharmacology. 2002;17(1):27-32. [pmid: 11800503].
49 Cassidy F, Weiner RD, Cooper TB, Carroll BJ. Combined catecholamine and indoleamine depletion following response to ECT. British Journal of Psychiatry. June. 2010;196(6):493-4. [pmid: 20513863].
50 Chandler GM, Iosifescu DV, Pollack MH, Targum SD, Fava M. Validation of the massachusetts general hospital Antidepressant Treatment History Questionnaire (ATRQ). CNS Neuroscience and Therapeutics. October. 2010;16(5):322-5. [pmid: 19769599].
51 Chapouthier G, Venault P. Mouse strains selected for differences in sensitivity to a benzodiazepine receptor inverse agonist: Pharmacological and behavioural responses. Biogenic Amines. 2002;17(3):185-97.
52 Chaput Y, Magnan A, Gendron A. The coadministration of quetiapine or placebo to cognitive-behavior therapy in treatment refractory depression: a preliminary trial. BMC Psychiatry. 2008;8:73. [pmid: 18752690].
53 Chaturvedi R, Sharma A, Sorrell JH. Electroconvulsive therapy in patients with vagus nerve stimulation. Journal of ECT. June. 2009;25(2):141-3. [pmid: 18665100].
54 Cheam EWS, Critchley LAH, Chui PT, Yap JCM, Ha VWS. Low dose mivacurium is less effective than succinylcholine in electroconvulsive therapy. Can J Anaesth. 1999;46(1):49-51. [pmid: 10078403].
55 Cheema FA, Badr A, Iqbal J. Glioblastoma multiforme presenting as treatment-resistant depression. Journal of Neuropsychiatry and Clinical Neurosciences. Winter. 2010;22(1):E26. [pmid: 20160235].
56 Chen PH, Cheng SJ. Restless legs syndrome among the elderly. International Journal of Gerontology. December. 2009;3(4):197-203.
57 Choukalas CG, Walter J, Glick D, O'Connor MF, Tung A, Dinwiddie SH, et al. Mask ventilation, hypocapnia, and seizure duration in electroconvulsive therapy. Journal of Clinical Anesthesia. 2010;22(6):415-9. [pmid: 20868961].
58 Citrome L. A review of aripiprazole in the treatment of patients with schizophrenia or bipolar I disorder. Neuropsychiatr Dis Treat. 2006;2(4):427-43. [pmid: 19412492].
59 Cohen RB, Boggio PS, Fregni F. Risk factors for relapse after remission with repetitive transcranial magnetic stimulation for the treatment of depression. Depression and Anxiety. July. 2009;26(7):682-8. [pmid: 19170101].
60 Cooper M. Cognitive behaviour therapy in an in-patient with chronic difficulties: A case report. Behavioural and Cognitive Psychotherapy. 1994;22(2):171-6.
61 Cotterill JA. Body dysmorphic disorder. Dermatologic Clinics. 1996;14(3):457-63. [pmid: 8818555].
62 Couturier JL. Efficacy of rapid-rate repetitive transcranial magnetic stimulation in the treatment of depression: A systematic review and meta-analysis. J Psychiatry Neurosci. 2005;30(2):83-90. [pmid: 15798783].
63 Dabkowska M, Rybakowski JK. Moclobemide in treatment-resistant depression. European Neuropsychopharmacology. 1993;3(3):328-9.
64 Daly JJ, Prudic J, Devanand DP, Nobler MS, Lisanby SH, Peyser S, et al. ECT in bipolar and unipolar depression: Differences in speed of response. Bipolar Disorders. 2001;3(2):95-104. [pmid: 11333069].
65 Dannon PN, Grunhaus L. Repetitive transcranial magnetic stimulation is effective following repeated courses in the treatment of major depressive disorder--a case report. Hum Psychopharmacol. Jun. 2003;18(4):313-5. [pmid: 12766937].
66 Daughters SB, Magidson JF, Schuster RM, Safren SA. ACT HEALTHY: A Combined Cognitive-Behavioral Depression and Medication Adherence Treatment for HIV-Infected Substance Users. Cognitive and Behavioral Practice. August. 2010;17(3):309-21. [pmid: 21709737].
67 De Mendonca Lima CA. The pharmacokinetic of antidepressants and resistant depressions. [Portuguese]. Jornal Brasileiro de Psiquiatria. 1988;37(3):149-55.
68 Dell'Osso B, Altamura AC. Augmentative transcranial magnetic stimulation (TMS) combined with brain navigation in drug-resistant rapid cycling bipolar depression: A case report of acute and maintenance efficacy. World Journal of Biological Psychiatry. 2009;10(4 PART 2):673-6. [pmid: 18956262].
69 Denys D, Mantione M, Figee M, Van Den Munckhof P, Koerselman F, Westenberg H, et al. Deep brain stimulation of the nucleus accumbens for treatment-refractory obsessive-compulsive disorder. Archives of general psychiatry. October. 2010;67(10):1061-8. [pmid: 20921122].
70 Devinsky O, Duchowny MS. Seizures after convulsive therapy: a retrospective case survey. Neurology. Jul. 1983;33(7):921-5. [pmid: 6683376].
71 Diazgranados N, Ibrahim L, Brutsche NE, Newberg A, Kronstein P, Khalife S, et al. A randomized add-on trial of an N-methyl-D-aspartate antagonist in treatment-resistant bipolar depression. Archives of General Psychiatry. August. 2010;67(8):793-802. [pmid: 20679587].
72 Dinan T. Treatment approaches to therapy-resistant depression. Journal of Psychopharmacology. 1995;9(2 SUPP):199-204.
73 Dinan TG. A rational approach to the nonresponding depressed patient. International Clinical Psychopharmacology. 1993;8(4):221-3. [pmid: 8277139].
74 Donohue A. First manic episode in a 55-year-old man after initiation of aripiprazole. Psychiatry (Edgemont). April. 2010;7(4):37-9.
75 Draper BM. The effectiveness of the treatment of depression in the physically ill elderly. Aging and Mental Health. 2000;4(1):9-20.
76 Dresler T, Ehlis AC, Plichta MM, Richter MM, Jabs B, Lesch KP, et al. Panic disorder and a possible treatment approach by means of high-frequency rTMS: A case report. World Journal of Biological Psychiatry. 2009;10(4 PART 3):991-7. [pmid: 19396702].
77 Dudek D, Siwek M, Borowiecka-Kluza J, Pawlowski T, Kiejna A, Lojko D, et al. q1Bipolar spectrum features in drug resistant unipolar depression patients: TRES-DEP pilot study. Archives of Psychiatry and Psychotherapy. June. 2009;11(2):65-73.
78 Dunner D, Kumar R. Paroxetine: A review of clinical experience. Pharmacopsychiatry. 1998;31(3):89-101. [pmid: 9657236].
79 Dunner DL, Rush AJ, Russell JM, Burke M, Woodard S, Wingard P, et al. Prospective, long-term, multicenter study of the naturalistic outcomes of patients with treatment-resistant depression. J Clin Psychiatry. May. 2006;67(5):688-95. [pmid: 16841617].
80 Epstein CM, Evatt ML, Funk A, Girard-Siqueira L, Lupei N, Slaughter L, et al. An open study of repetitive transcranial magnetic stimulation in treatment-resistant depression with Parkinson's disease. Clin Neurophysiol. Oct. 2007;118(10):2189-94. [pmid: 17714987].
81 Eranti S, Mogg A, Pluck G, Landau S, Purvis R, Brown RG, et al. A randomized, controlled trial with 6-month follow-up of repetitive transcranial magnetic stimulation and electroconvulsive therapy for severe depression. Am J Psychiatry. Jan. 2007;164(1):73-81. [pmid: 17202547].
82 Erdil F, Demirbilek S, Begec Z, Ozturk E, Ersoy MO. Effects of propofol or etomidate on QT interval during electroconvulsive therapy. Journal of ECT. September. 2009;25(3):174-7. [pmid: 19225403].
83 Etches SM, Schmidt M, Alda M, Hajek T, Kahn DA. Resolution of bipolar II and panic disorders following subarachnoid hemorrhage. Journal of Psychiatric Practice. March. 2009;15(2):145-9. [pmid: 19339849].
84 Faison WE, Steffens DC. Diagnosis, epidemiology, and clinical course of geriatric depression. Economics of Neuroscience. 2001;3(7):40-3.
85 Farzan F, Barr MS, Levinson AJ, Chen R, Wong W, Fitzgerald PB, et al. Evidence for gamma inhibition deficits in the dorsolateral prefrontal cortex of patients with schizophrenia. Brain. May. 2010;133(5):1505-14. [pmid: 20350936].
86 Fava M, Rush AJ, Trivedi MH, Nierenberg AA, Thase ME, Sackeim HA, et al. Background and rationale for the sequenced treatment alternatives to relieve depression (STAR*D) study. Psychiatric Clinics of North America. 2003;26(2):457-94. [pmid: 12778843].
87 Fawcett J. Why aren't MAOIs used more often?. Journal of Clinical Psychiatry. January. 2009;70(1):139-40. [pmid: 19222985].
88 Fear CF, Littlejohns S, Rouse E, McQuail P. Propofol anaesthesia in electroconvulsive therapy. Reduced seizure duration may not be relevant. British Journal of Psychiatry. 1994;165(OCT):506-9. [pmid: 7848492].
89 Feinberg SS. Combining stimulants with monoamine oxidase inhibitors: a review of uses and one possible additional indication. The Journal of clinical psychiatry. Nov. 2004;65(11):1520-4. [pmid: 15554766].
90 Fenton WS. Evolving perspectives on individual psychotherapy for schizophrenia. Schizophrenia Bulletin. 2000;26(1):47-72. [pmid: 10755669].
91 Fernandez-Llimos F, Tuneu L, Baena MI, Garcia-Delgado A, Faus MJ. Morbidity and mortality associated with pharmacotherapy. Evolution and current concept of drug-related problems. Current Pharmaceutical Design. 2004;10(31):3947-67. [pmid: 15579082].
92 Ferreri F, Agbokou C, Gauthier S. Recognition and management of neuropsychiatric complications in Parkinson's disease. Canadian Medical Association Journal. 2006;175(12):1545-52. [pmid: 17146092].
93 Ferrucci R, Bortolomasi M, Brunoni A, Vergari M, Tadini L, Giacopuzzi M, et al. Comparative benefits of transcranial direct current stimulation (TDCS) treatment in patients with mild/moderate vs. severe depression. Clinical Neuropsychiatry. December. 2009;6(6):246-51.
94 Fiske A, Wetherell JL, Gatz M. Depression in older adults, General Pathology and Pathological Anatomy. United States. Annual Reviews Inc. 2009:363-89.
95 Fountoulakis KN, Vieta E. Treatment of bipolar disorder: A systematic review of available data and clinical perspectives. International Journal of Neuropsychopharmacology. 2008;11(7):999-1029. [pmid: 18752718].
96 Franzini A, Messina G, Marras C, Savino M, Miniati M, Bugiani O, et al. Hamilton rating scale for depression-21 modifications in patients with vagal nerve stimulation for treatment of treatment-resistant depression: Series report. Neuromodulation. November. 2008;11(4):267-71.
97 Fu W, Stool LA, White PF, Husain MM. Acute hemodynamic responses to electroconvulsive therapy are not related to the duration of seizure activity. Journal of Clinical Anesthesia. 1997;9(8):653-7. [pmid: 9438894].
98 Fu W, Stool LA, White PF, Husain MM. Is oral clonidine effective in modifying the acute hemodynamic response during electroconvulsive therapy?. Anesth Analg. 1998;86(5):1127-30. [pmid: 9585310].
99 Fugate SE, Ramsey AM. Resistance to oral vitamin K for reversal of overanticoagulation during Crohn's disease relapse. Journal of Thrombosis and Thrombolysis. 2004;17(3):219-23. [pmid: 15353921].
100 Gabbard GO. How not to teach psychotherapy. Academic Psychiatry. 2005;29(4):332-8. [pmid: 16223894].
101 Gaete JM, Bogousslavsky J. Post-stroke depression. Expert Review of Neurotherapeutics. 2008;8(1):75-92. [pmid: 18088202].
102 Garcia KS, Flynn P, Pierce KJ, Caudle M. Repetitive transcranial magnetic stimulation treats postpartum depression. Brain Stimulation. January. 2010;3(1):36-41. [pmid: 20633429].
103 Gazdag G, Kocsis N, Tolna J, Ivanyi Z. Etomidate versus propofol for electroconvulsive therapy in patients with schizophrenia. J ECT. 2004;20(4):225-9. [pmid: 15591855].
104 Gelenberg AJ, Hopkins HS. Report on efficacy of treatments for bipolar disorder. Psychopharmacology Bulletin. 1993;29(4):447-56. [pmid: 8084977].
105 George MS, Rush AJ, Marangell LB, Sackeim HA, Brannan SK, Davis SM, et al. A one-year comparison of vagus nerve stimulation with treatment as usual for treatment-resistant depression. Biol Psychiatry. Sep. 1. 2005;58(5):364-73. [pmid: 16139582].
106 Ghaemi SN, Schrauwen E, Klugman J, Berv DA, Shirzadi AA, Pardo TB, et al. Long-term lamotrigine plus lithium for bipolar disorder: One year outcome. Journal of Psychiatric Practice. 2006;12(5):300-5. [pmid: 16998417].
107 Gibson RC, Walcott G. Benzodiazapines for catatonia in persons with schizophrenia and other serious mental illnesses. Cochrane Database of Systematic Reviews. 2007;(2).
108 Gibson TB, Jing Y, Carls GS, Kim E, Bagalman JE, Burton WN, et al. Cost burden of treatment resistance in patients with depression. American Journal of Managed Care. May. 2010;16(5):370-7. [pmid: 20469957].
109 Gieteling M, Hoekstra R, Van Den Broek WW, Bruijn JA. Continuation treatment with electroconvulsive therapy in depression resistant to medication. [Dutch]. Nederlands Tijdschrift voor Geneeskunde. 1998;142(38):2110-2. [pmid: 9856226].
110 Gill DS, Ketter TA, Post RM. Antidepressant response to sleep deprivation as a function of time into depressive episode in rapidly cycling bipolar patients. Acta Psychiatrica Scandinavica. 1993;87(2):102-9. [pmid: 8447235].
111 Ginsberg DL. Low dose oral for selegiline for severe refractory depression. Primary Psychiatry. Jan. 2006;13(1):26-7.
112 Ginsberg DL. Aripiprazole augmentation of clomipramine-refractory obsessive-compulsive disorder. Primary Psychiatry. 2007;14(8):19-20.
113 Giovagnoli AR, Villani F, Bell B, Erbetta A, Avanzini G. The chicken with four legs: A case of semantic amnesia and cryptogenic epilepsy. Epilepsy and Behavior. January. 2009;14(1):261-8. [pmid: 18930165].
114 Goforth HW, Carroll BT. Aripiprazole augmentation of tranylcypromine in treatment-resistant major depression [8]. Journal of Clinical Psychopharmacology. Apr. 2007;27(2):216-7. [pmid: 17414252].
115 Goldberg D. The “NICE Guideline” on the treatment of depression. Epidemiologia e Psichiatria Soc. 2006;15(1):11-5.
116 Golden RN, Evans DL, Sullivan MD. Antidepressants and tinnitus [2]. Archives of Internal Medicine. 1994;154(12).
117 Goodnick PJ, Barrios CA. Use of olanzapine in non-psychotic psychiatric disorders. Expert Opinion on Pharmacotherapy. 2001;2(4):667-80. [pmid: 11336615].
118 Gormley N. ECT should be treatment option in all cases of refractory depression [7]. British Medical Journal. 1998;316(7126):233. [pmid: 9468718].
119 Gouvea F, Lopes A, Greenberg B, Canteras M, Taub A, Mathis M, et al. Response to sham and active gamma ventral capsulotomy in otherwise intractable obsessive-compulsive disorder. Stereotactic and Functional Neurosurgery. May. 2010;88(3):177-82. [pmid: 20431329].
120 Grati L, Louzi M, Nasr KB, Zili N, Mansalli L, Mechri A, et al. Compared effects of etomidate and propofol for anaesthesia during electroconvulsive therapy. Presse Medicale. 2005;34(4):282-4.
121 Greist JH, McElroy. Behavior therapy for obsessive compulsive disorder. J Clin Psychiatry. 1994;55(10 SUPPL):60-8. [pmid: 7961534].
122 Grover M, Dorn SD, Weinland SR, Dalton CB, Gaynes BN, Drossman DA. Atypical antipsychotic quetiapine in the management of severe refractory functional gastrointestinal disorders. Digestive Diseases and Sciences. June. 2009;54(6):1284-91. [pmid: 19242800].
123 Grunhaus L, Dannon PN, Schreiber S, Dolberg OH, Amiaz R, Ziv R, et al. Repetitive transcranial magnetic stimulation is as effective as electroconvulsive therapy in the treatment of nondelusional major depressive disorder: an open study. Biol Psychiatry. Feb. 15. 2000;47(4):314-24. [pmid: 10686266].
124 Grunhaus L, Remen A. Assessment of treatment-resistant major depression - The Michigan adequacy of treatment scale [4]. Journal of Clinical Psychopharmacology. 1993;13(3):221-3. [pmid: 8354741].
125 Grunhaus L, Schreiber S, Dolberg OT, Polak D, Dannon PN. A randomized controlled comparison of electroconvulsive therapy and repetitive transcranial magnetic stimulation in severe and resistant nonpsychotic major depression. Biol Psychiatry. 2003:324-31.
126 Guthrie SK, Sung JCY, Goodson J, Grunhaus L, Tandon R. Triazolam and diphenhydramine effects on seizure duration in depressed patients receiving ECT. Convulsive Therapy. 1996;12(4):261-5. [pmid: 9034702].
127 Hamelin S, Kahane P, Vercueil L. Fatigue in epilepsy: A prospective inter-ictal and post-ictal survey. Epilepsy Research. October. 2010;91(2-3):153-60. [pmid: 20708384].
128 Hanisch F, Friedemann J, Piro J, Gutmann P. Maintenance electroconvulsive therapy for comorbid pharmacotherapy- refractory obsessive-compulsive and schizoaffective disorder. European Journal of Medical Research. 12. Aug. 2009;14(8):367-8. [pmid: 19666398].
129 Hardy P, Feline A. Refractory depressions. [French]. Semaine des Hopitaux. 1988;64(36-37):2421-4.
130 Harris SJ, Parent M. Patient with chronic and apparently treatment-resistant dysthymia. The American journal of psychiatry. Feb. 1986;143(2):260-1. [pmid: 3946673].
131 Hausmann A, Kemmler G, Walpoth M, Mechtcheriakov S, Kramer-Reinstadler K, Lechner T, et al. No benefit derived from repetitive transcranial magnetic stimulation in depression: A prospective, single centre, randomised, double blind, sham controlled “add on” trial. Journal of Neurology, Neurosurgery and Psychiatry. 2004;75(2):320-2.
132 He W, Chai H, Zhang Y, Yu S, Chen W, Wang W. Line bisection performance in patients with generalized anxiety disorder and treatment-resistant depression. International Journal of Medical Sciences. 2010;7(4):224-31. [pmid: 20617126].
133 Heldt E, Manfro GG, Kipper L, Blaya C, Isolan L, Otto MW. One-year follow-up of pharmacotherapy-resistant patients with panic disorder treated with cognitive-behavior therapy: Outcome and predictors of remission. Psychotherapy and Psychosomatics. 2006;44(5):657-65.
134 Hermann RC, Ettner SL, Dorwart RA, Langman-Dorwart N, Kleinman S. Diagnoses of patients treated with ECT: A comparison of evidence-based standards with reported use. Psychiatric Services. 1999;50(8):1059-65. [pmid: 10445655].
135 Hiremani RM, Thirthalli J, Tharayil BS, Gangadhar BN. Double-blind randomized controlled study comparing short-term efficacy of bifrontal and bitemporal electroconvulsive therapy in acute mania. Bipolar Disorders. 2008;10(6):701-7. [pmid: 18837864].
136 Hirschfeld RMA, Clayton PJ, Cohen I, Fawcett J, Keck P, McClellan J, et al. Practice guideline for the treatment of patients with bipolar disorder. American Journal of Psychiatry. 1994;151(12 SUPPL):1-36.
137 Hixson JD, Kirsch HE. The effects of epilepsy and its treatments on affect and emotion. Neurocase. June. 2009;15(3):206-16. [pmid: 19204849].
138 Hofmann G, Schony W. Therapy-resistant depressions. [German]. Psychiatria Danubina. 1989;1(2):131-4.
139 Hornby AP, Sharma M, Stegman B. Standardized natural product cannabis in pain management and observations at a Canadian compassion society: A case report. Cases Journal. May. 2009;2(5):7487. [pmid: 19829975].
140 Hrdlicka M, Blatny M, Urbanek T, Moran M, Manasova I. Electroconvulsive therapy: Does a history of pharmacoresistance influence the therapeutic response?. [Czech]. Ceska a Slovenska Psychiatrie. 2001;97(2):56-9.
141 Hupfeld Moreno D, Moreno RA. Resistant depressions: Treatment approach. [Portuguese]. Jornal Brasileiro de Psiquiatria. 1993;42(SUPPL. 1).
142 Iosifescu DV, Bankier B, Fava M. Impact of medical comorbid disease on antidepressant treatment of major depressive disorder. Current Psychiatry Reports. 2004;6(3):193-201. [pmid: 15142472].
143 Ivanyi Z, Tolna J, Gazdag G. Impact of propofol and etomidate on seizure activity during electroconvulsive therapy in patients with schizophrenia [59]. Anesthesia and Analgesia. 2007;104(1):241. [pmid: 17179316].
144 Jakovljevic M, Filakovic P, Ljubicic D. Die Behandlung Der Gegen Ubliche Psychopharmakotherapie Resistenten Affektiven Storungen. Psychiatria Danubina. 1992;4(1-2):119-26.
145 Janakiramaiah N, Motreja S, Gangadhar BN, Subbakrishna DK, Parameshwara G. Once vs. three times weekly ECT in melancholia: A randomized controlled trial. Acta Psychiatrica Scandinavica. 1998;98(4):316-20. [pmid: 9821454].
146 Jenike MA. Pharmacologic treatment of obsessive compulsive disorders. Psychiatric Clinics of North America. 1992;15(4):895-919. [pmid: 1461804].
147 Jenike MA. Psychiatric illnesses in the elderly: A review. Journal of Geriatric Psychiatry and Neurology. 1996;9(2):57-82. [pmid: 8736587].
148 Jeronimo A, Meira C, Amaro A, Campello GC, Granja C. Cardiogenic shock caused by disulfiram. [Spanish, Portuguese, English]. Arquivos Brasileiros de Cardiologia. March. 2009;92(3):e16-e8. [pmid: 19390700].
149 Jurysta F, Kempenaers C, Lancini J, Lanquart JP, Van De Borne P, Linkowski P. Altered interaction between cardiac vagal influence and delta sleep EEG suggests an altered neuroplasticity in patients suffering from major depressive disorder: Brief communication. Acta Psychiatrica Scandinavica. March. 2010;121(3):236-9. [pmid: 19764928].
150 Kafantaris V. Treatment of bipolar disorder in children and adolescents. Journal of the American Academy of Child and Adolescent Psychiatry. 1995;34(6):732-41. [pmid: 7608046].
151 Kahn DA, Sachs GS, Printz DJ, Carpenter D, Docherty JP, Ross R. Expert consensus guidelines for the medication treatment of bipolar disorder: A new treatment tool. Postgrad Med. 2001;3(1):49-57.
152 Kapfhamer J, Russeth K, Heinrich T. Subcutaneous injection of intranasal canine kennel cough vaccine. Psychosomatics. March-April. 2009;50(2):180. [pmid: 19377032].
153 Kapural L, Lokey K, Leong MS, Fiekowsky S, Stanton-Hicks M, Sapienza-Crawford AJ, et al. Intrathecal ziconotide for complex regional pain syndrome: Seven case reports. Pain Practice. 2009;9(4):296-303. [pmid: 19500276].
154 Kaufman CB, Mink JW, Schwalb JM. Bilateral deep brain stimulation for treatment of medically refractory paroxysmal nonkinesigenic dyskinesia. Journal of Neurosurgery. April. 2010;112(4):847-50. [pmid: 19799495].
155 Kerrigan F. Antidepressant patents: 1995-1997. Expert Opinion on Therapeutic Patents. 1998;8(4):439-60.
156 Kessler U, Vaaler AE, Schoyen H, Oedegaard KJ, Bergsholm P, Andreassen OA, et al. The study protocol of the Norwegian randomized controlled trial of electroconvulsive therapy in treatment resistant depression in bipolar disorder. BMC Psychiatry. 2010;10:16. [pmid: 20178636].
157 Khalid I, Rana L, Khalid TJ, Roehrs T. Refractory restless legs syndrome likely caused by olanzapine. Journal of Clinical Sleep Medicine. 15. Feb. 2009;5(1):68-9. [pmid: 19317385].
158 Khan A, Mirolo MH, Lai H, Claypoole K, Bierut L, Malik R, et al. ECT and TRH: Cholinergic involvement in a cognitive deficit state. Psychopharmacology Bulletin. 1993;29(3):345-52. [pmid: 8121962].
159 Kimmel PL, Levy N, Vassalotti J, Christensen A, Friend R, Veis J, et al. Psychosocial factors in dialysis patients. Kidney International. 2001;59(4):1599-613. [pmid: 11260433].
160 Kivela SL. Treatment of depressive disorders in old age. Current Opinion in Psychiatry. 2001;14(4):387-93.
161 Kojima H, Terao T, Yoshimura R. Serotonin syndrome during clomipramine and lithium treatment [1]. American Journal of Psychiatry. 1993;150(12).
162 Kok RM, Nolen WA, Heeren TJ. Outcome of late-life depression after 3 years of sequential treatment. Acta Psychiatrica Scandinavica. 2009;119(4):274-81. [pmid: 19053970].
163 Kok RM, Van Maarschalkerweerd WWA. Treatment resistant depression in the elderly; when is it inadvisable to prescribe tricyclic antidepressants?. [Dutch]. Tijdschrift voor Psychiatrie. 2004;46(11):769-73.
164 Kuba R, Novotna I, Brazdil M, Kocvarova J, Tyrlikova I, Mastik J, et al. Long-term levetiracetam treatment in patients with epilepsy: 3-year follow up. Acta Neurologica Scandinavica. February. 2010;121(2):83-8. [pmid: 20003081].
165 Kubera M, Maes M, Budziszewska B, Basta-Kaim A, Leskiewicz M, Grygier B, et al. Inhibitory effects of amantadine on the production of pro-inflammatory cytokines by stimulated in vitro human blood. Pharmacological Reports. 2009;61(6):1105-12. [pmid: 20081246].
166 Kucia KA, Stepanczak R, Tredzbor B. Electroconvulsive therapy for major depression in an elderly person with epilepsy. World Journal of Biological Psychiatry. 2009;10(1):78-80. [pmid: 19673091].
167 Kuehnert MJ, Webb RM, Jochimsen EM, Hancock GA, Arduino MJ, Hand S, et al. Staphylococcus aureus bloodstream infections among patients undergoing electroconvulsive therapy traced to breaks in infection control and possible extrinsic contamination by propofol. Anesthesia and Analgesia. 1997;85(2):420-5. [pmid: 9249124].
168 Lai CH. Mirtazapine and Bupropion Combined Treatment in Treatment-resistant Depression. Tzu Chi Medical Journal. December. 2009;21(4):352-4.
169 Leftheriotis D, Flevari P, Ikonomidis I, Douzenis A, Liapis C, Paraskevaidis I, et al. The role of the selective serotonin re-uptake inhibitor sertraline in nondepressive patients with chronic ischemic heart failure: A preliminary study. PACE - Pacing and Clinical Electrophysiology. October. 2010;33(10):1217-23.
170 Leon AC, Hedeker D. A comparison of mixed-effects quantile stratification propensity adjustment strategies for longitudinal treatment effectiveness analyses of continuous outcomes. Statistics in Medicine. 2007;26(13):2650-65. [pmid: 17094068].
171 Levene M. Recognition and management of neonatal seizures. Paediatrics and Child Health. 2008;18(4):178-82.
172 Levine J, Mishori A, Susnosky M, Martin M, Belmaker RH. Combination of inositol and serotonin reuptake inhibitors in the treatment of depression. Biological Psychiatry. 1999;45(3):270-3. [pmid: 10023500].
173 Levkovitz Y, Harel EV, Roth Y, Braw Y, Most D, Katz LN, et al. Deep transcranial magnetic stimulation over the prefrontal cortex: Evaluation of antidepressant and cognitive effects in depressive patients. Brain Stimulation. October. 2009;2(4):188-200. [pmid: 20633419].
174 Levy ML, Levy KM, Hoff D, Amar AP, Park MS, Conklin JM, et al. Vagus nerve stimulation therapy in patients with autism spectrum disorder and intractable epilepsy: Results from the vagus nerve stimulation therapy patient outcome registry - Clinical article. Journal of Neurosurgery: Pediatrics. June. 2010;5(6):595-602. [pmid: 20515333].
175 Licht CMM, De Geus EJC, Van Dyck R, Penninx BWJH. Longitudinal evidence for unfavorable effects of antidepressants on heart rate variability. Biological Psychiatry. 2010;68(9):861-8. [pmid: 20843507].
176 Licht RW, Gijsman H, Nolen WA, Angst J. Are antidepressants safe in the treatment of bipolar depression? A critical evaluation of their potential risk to induce switch into mania or cycle acceleration. Acta Psychiatrica Scandinavica. 2008;118(5):337-46. [pmid: 18754834].
177 Licht RW, Vestergaard P, Brodersen A. Long-term outcome of patients with bipolar disorder commenced on lithium prophylaxis during hospitalization: A complete 15-year register-based follow-up. Bipolar Disorders. 2008;10(1):79-86. [pmid: 18199244].
178 Lieberman A. An integrated approach to patient management in Parkinson's disease. Neurologic Clinics. 1992;10(2):553-65. [pmid: 1350053].
179 Lieberman JA, Greenhouse J, Hamer RM, Krishnan KR, Nemeroff CB, Sheehan DV, et al. Comparing the effects of antidepressants: Consensus guidelines for evaluating quantitative reviews of antidepressant efficacy. Neuropsychopharmacology. 2005;30(3):445-60. [pmid: 15647752].
180 Lindenmayer JP, Alcantara F, Khan A, Ciranni M. The effects of molindone as a concomitant medication on aggressive behavior. Clinical Schizophrenia and Related Psychoses. 01. Jan. 2010;3(4):193-200.
181 Lisanby SH, Luber B, Schlaepfer TE, Sackeim HA. Safety and feasibility of magnetic seizure therapy (MST) in major depression: randomized within-subject comparison with electroconvulsive therapy. Neuropsychopharmacology. Oct. 2003;28(10):1852-65. [pmid: 12865903].
182 Little JT, Reynolds ICF, Dew MA, Frank E, Begley AE, Miller MD, et al. How common is resistance to treatment in recurrent, nonpsychotic geriatric depression?. American Journal of Psychiatry. 1998;155(8):1035-8. [pmid: 9699690].
183 Loo C, Martin D, Pigot M, Arul-Anandam P, Mitchell P, Sachdev P. Transcranial direct current stimulation priming of therapeutic repetitive transcranial magnetic stimulation: A pilot study. Journal of ECT. December. 2009;25(4):256-60. [pmid: 19440158].
184 Loo CK, Kaill A, Paton P, Simpson B. The difficult-to-treat electroconvulsive therapy patient - Strategies for augmenting outcomes. Journal of affective disorders. August. 2010;124(3):219-27. [pmid: 19647325].
185 Machado-Vieira R, Soares JC. Treatment-resistant mood disorders. [Portuguese, English]. Revista Brasileira de Psiquiatria. 2007;29(SUPPL. 2):S48-S54. [pmid: 17713691].
186 Maes M. “Functional” or “psychosomatic” symptoms, e.g. a flu-like malaise, aches and pain and fatigue, are major features of major and in particular of melancholic depression. Neuroendocrinology Letters. 2009;30(5):564-73. [pmid: 20035251].
187 Maizels M. Clonazepam for refractory headache: Three cases illustrative of benefit and risk. Headache. April. 2010;50(4):650-6. [pmid: 20236347].
188 Malison RT, Anand A, Pelton GH, Kirwin P, Carpenter L, McDougle CJ, et al. Limited efficacy of ketoconazole in treatment-refractory major depression. Journal of Clinical Psychopharmacology. 1999;19(5):466-70. [pmid: 10505589].
189 Mantovani A, Lisanby SH, Pieraccini F, Ulivelli M, Castrogiovanni P, Rossi S. Repetitive Transcranial Magnetic Stimulation (rTMS) in the treatment of panic disorder (PD) with comorbid major depression. J Affect Disord. Sep. 2007;102(1-3):277-80. [pmid: 17215046].
190 Martin-Blanco A, Pascual JC, Soler J, Valdeperez A, Perez V. Quetiapine in the treatment of refractory irritable bowel syndrome. A case report. Progress in Neuro-Psychopharmacology and Biological Psychiatry. May. 2010;34(4):715-6. [pmid: 20298733].
191 Massol J, Martin P, Belon JP, Puech AJ, Soubrie P. Helpless behavior (escape deficits) in streptozotocin-diabetic rats: Resistance to antidepressant drugs. Psychoneuroendocrinology. 1989;14(1-2):145-53. [pmid: 2544000].
192 Mayur PM, Shree RS, Gangadhar BN, Subbakrishna DK, Janakiramaiah N, Rao GSU. Atropine premedication and the cardiovascular response to electroconvulsive therapy. British Journal of Anaesthesia. 1998;81(3):466-7. [pmid: 9861141].
193 Mazeh D, Melamed Y, Elizur A. Venlafaxine in the treatment of resistant postpsychotic depressive symptoms of schizophrenia [8]. Journal of Clinical Psychopharmacology. 1999;19(3):284-5. [pmid: 10350042].
194 Mazza M, Di Nicola M, Martinotti G, Taranto C, Janiri L, Bria P, et al. Treatment of schizophrenia. Minerva Psichiatrica. 2007;48(1):43-53.
195 McCall WV, Farah BA, Reboussin D, Colenda CC. Comparison of the efficacy of titrated, moderate-dose and fixed, high- dose right unilateral ECT in elderly patients. American Journal of Geriatric Psychiatry. 1995;3(4):317-24.
196 McCall WV, Sparks W, Jane J, Rosenquist PB, Colenda CC, Reboussin DM. Variation of ictal electroencephalographic regularity with low-, moderate-, and high-dose stimuli during right unilateral electroconvulsive therapy. Biological Psychiatry. 1998;43(8):608-11. [pmid: 9564446].
197 McCormick LM, Brumm MC, Benede AK, Lewis JL. Relative ineffectiveness of ultrabrief right unilateral versus bilateral electroconvulsive therapy in depression. Journal of ECT. December. 2009;25(4):238-42. [pmid: 19384251].
198 McNamara B, Ray JL, Arthurs OJ, Boniface S. Transcranial magnetic stimulation for depression and other psychiatric disorders. Psychological Medicine. 2001;31(7):1141-6. [pmid: 11681540].
199 Mhalla A, de Andrade DC, Baudic S, Perrot S, Bouhassira D. Alteration of cortical excitability in patients with fibromyalgia. Pain. June. 2010;149(3):495-500. [pmid: 20356675].
200 Minelli A, Bortolomasi M, Scassellati C, Salvoro B, Avesani M, Manganotti P. Effects of intravenous antidepressant drugs on the excitability of human motor cortex: a study with paired magnetic stimulation on depressed patients. Brain Stimulation. January. 2010;3(1):15-21. [pmid: 20633426].
201 Mingli H, Zhengtian G, Xinyi W, Xiaoping T. Effects of repetitive transcranial magnetic stimulation on hypothalamic-pituitary-adrenal axis of patients with depression. Journal of Medical Colleges of PLA. December. 2009;24(6):337-45.
202 Mitchell PB. Management of treatment-resistant depression in the late 1990s. Hong Kong Journal of Psychiatry. 1999;9(1):3-11.
203 Mizrak A, Koruk S, Ganidagli S, Bulut M, Oner U. Premedication with dexmedetomidine and midazolam attenuates agitation after electroconvulsive therapy. Journal of Anesthesia. 2009;23(1):6-10. [pmid: 19234815].
204 Mogg A, Pluck G, Eranti SV, Landau S, Purvis R, Brown RG, et al. A randomized controlled trial with 4-month follow-up of adjunctive repetitive transcranial magnetic stimulation of the left prefrontal cortex for depression. Psychol Med. Mar. 2008;38(3):323-33. [pmid: 17935639].
205 Mohan TSP, Tharyan P, Alexander J, Raveendran NS. Effects of stimulus intensity on the efficacy and safety of twice-weekly, bilateral electroconvulsive therapy (ECT) combined with antipsychotics in acute mania: A randomised controlled trial. Bipolar Disorders. 2009;11(2):126-34. [pmid: 19267695].
206 Morgan PT. Treatment-resistant depression: Response to low-dose transdermal but not oral selegiline [10]. Journal of Clinical Psychopharmacology. Jun. 2007;27(3):313-4. [pmid: 17502787].
207 Morra E, Lazzarino M, Alimena G, Liberati AM, Grignani F, Mandelli F, et al. The role of interferon in the treatment of chronic myelogenous leukemia: Results and prospects. Leukemia and Lymphoma. 1992;6(4-5):305-15.
208 Mufti MA, Holtzheimer IPE, Epstein CM, Quinn SC, Vito N, McDonald WM. Bupropion decreases resting motor threshold: A case report. Brain Stimulation. 2010;3(3):177-80. [pmid: 20633447].
209 Mulder RT, Joyce PR, Frampton CMA. Personality disorders improve in patients treated for major depression. Acta Psychiatrica Scandinavica. September. 2010;122(3):219-25. [pmid: 19895619].
210 Muller H, Demling JH, Schutz P, Weigel D, Kornhuber J, Sperling W. Safety of vagus nerve stimulation in a patient with bipolar disorder and an implanted cardioverter-defibrillator. Acta Neurologica Scandinavica. April. 2010;121(4):285-6. [pmid: 20175760].
211 Muller N. Tourette's syndrome: Clinical features, pathophysiology, and therapeutic approaches. Dialogues in Clinical Neuroscience. 2007;9(2):161-71. [pmid: 17726915].
212 Munk-Olsen T, Laursen TM, Videbech P, Mortensen PB, Rosenberg R. All-cause mortality among recipients of electroconvulsive therapy: Register-based cohort study. British Journal of Psychiatry. 2007;190(MAY):435-9. [pmid: 17470959].
213 Murray G, Michalak EE, Axler A, Yaxley D, Hayashi B, Westrin A, et al. Relief of Chronic or Resistant Depression (Re-ChORD): A pragmatic, randomized, open-treatment trial of an integrative program intervention for chronic depression. Journal of Affective Disorders. June. 2010;123(1-3):243-8. [pmid: 19896200].
214 Myers A, Barrueto F Jr. Refractory priapism associated with ingestion of yohimbe extract. Journal of Medical Toxicology. 2009;5(4):223-5. [pmid: 19876857].
215 Nahas Z, Kozel FA, Li X, Anderson B, George MS. Left prefrontal transcranial magnetic stimulation (TMS) treatment of depression in bipolar affective disorder: a pilot study of acute safety and efficacy. Bipolar Disord. Feb. 2003;5(1):40-7. [pmid: 12656937].
216 Naz B, Craig TJ, Bromet EJ, Finch SJ, Fochtmann LJ, Carlson GA. Remission and relapse after the first hospital admission in psychotic depression: A 4-year naturalistic follow-up. Psychological Medicine. 2007;37(8):1173-81. [pmid: 17335639].
217 Ng B. The role of psychostimulants in psychogeriatrics: A New Zealand survey. Psychogeriatrics. September. 2009;9(3):121-6.
218 Nguyen TT, Chhibber AK, Lustik SJ, Kolano JW, Dillon PJ, Guttmacher LB. Effect of methohexitone and propofol with or without alfentanil on seizure duration and recovery in electroconvulsive therapy. British Journal of Anaesthesia. 1997;79(6):801-3. [pmid: 9496217].
219 Nierenberg AA. Low-dose buspirone, melatonin and low-dose bupropion added to mood stabilizers for severe treatment-resistant bipolar depression. Psychotherapy and Psychosomatics. 2009;78(6):391-3. [pmid: 19738411].
220 Nierenberg AA, Trivedi MH, Gaynes BN, Mitchell J, Davis LL, Husain MM, et al. Effectiveness study of venlafaxine-XR combined with aripiprazole for chronic or recurrent major depressive disorder. Australian and New Zealand Journal of Psychiatry. 2009;43(10):956-67.
221 Nikolajsen L, Jensen TS. Phantom limb pain. British Journal of Anaesthesia. 2001;87(1):107-16. [pmid: 11460799].
222 Nolen WA, Van Den Broek WW, Birkenhager TK. Treatment with low doses of tranylcypromine resulted in a disappointing remission rate [1]. American Journal of Psychiatry. 2007;164(3):524. [pmid: 17329480].
223 Nomoto K, Suzuki T, Serada K, Oe K, Yoshida T, Yamada S. Effects of landiolol on hemodynamic response and seizure duration during electroconvulsive therapy. Journal of Anesthesia. 2006;20(3):183-7. [pmid: 16897237].
224 O'Connor MG, Jerskey BA, Robertson EM, Brenninkmeyer C, Ozdemir E, Leone AP. The effects of repetitive transcranial magnetic stimulation (rTMS) on procedural memory and dysphoric mood in patients with major depressive disorder. Cogn Behav Neurol. Dec. 2005;18(4):223-7. [pmid: 16340396].
225 Ogawa S, Okutani R, Suehiro K, Shigemoto T. Refractory hypotension during remifentanil-based anesthesia in a patient receiving long-term antidepressant therapy. Anesthesia and Resuscitation. March. 2009;45(1):27-9.
226 Okabe S, Ugawa Y, Kanazawa I. 0.2-Hz repetitive transcranial magnetic stimulation has no add-on effects as compared to a realistic sham stimulation in parkinson's disease. Movement Disorders. 2003;18(4):382-8. [pmid: 12671943].
227 Okamoto H, Shimizu E, Ozawa K, Hashimoto K, Iyo M. Lithium augmentation in milnacipran-refractory depression for the prevention of relapse following electroconvulsive therapy [1]. Australian and New Zealand Journal of Psychiatry. Jan. 2005;39(1-2):108. [pmid: 15660714].
228 Okay T, Sengul C, Gulunay A, Sengul CB, Erken DD, Dilbaz N. The short term effects of naproxen sodium on treatment satisfaction and headache as a side-effect of electroconvulsive therapy: A preliminary study. Klinik Psikofarmakoloji Bulteni. 2008;18(1):41-5.
229 O'Leary D, Gill D, Gregory S, Shawcross C. Which depressed patients respond to ECT? The Nottingham results. Journal of Affective Disorders. 1995;33(4):245-50. [pmid: 7790678].
230 Ordas DM, Ritchie EC. Treatment of depersonalization disorder and associated depression with electroconvulsive therapy [8]. Journal of Neuropsychiatry and Clinical Neurosciences. 1994;6(1):67-9. [pmid: 8148644].
231 Osser DN. A systematic approach to the classification and pharmacotherapy of nonpsychotic major depression and dysthymia. Journal of Clinical Psychopharmacology. 1993;13(2):133-44. [pmid: 8463446].
232 Otsuka T, Togo T, Sugiyama N, Uehara K, Yoshimi A, Karashima A, et al. Perospirone augmentation of paroxetine in treatment of refractory obsessive-compulsive disorder with depression. Progress in Neuro-Psychopharmacology and Biological Psychiatry. 30. Mar. 2007;31(2):564-6. [pmid: 17166643].
233 Ottaviani C, Shapiro D, Davydov DM, Goldstein IB, Mills PJ. The autonomic phenotype of rumination. International Journal of Psychophysiology. June. 2009;72(3):267-75. [pmid: 19272312].
234 Otter M, Cohen D. Electroconvulsive therapy in depressed adolescent [3]. Nederlands Tijdschrift voor Geneeskunde. 2007;151(47):2643-4. [pmid: 18161268].
235 Ozcan ME, Suppes T. Methyltestosterone add-on in bipolar depression: A case report. Klinik Psikofarmakoloji Bulteni. 2009;19(SUPPL. 1):S166-S7.
236 Paillere Martinot ML, Galinowski A, Ringuenet D, Gallarda T, Lefaucheur JP, Bellivier F, et al. Influence of prefrontal target region on the efficacy of repetitive transcranial magnetic stimulation in patients with medication-resistant depression: A [18F]-fluorodeoxyglucose PET and MRI study. International Journal of Neuropsychopharmacology. 2010:45-59.
237 Pal E, Nagy F, Aschermann Z, Balazs E, Kovacs N. The impact of left prefrontal repetitive transcranial magnetic stimulation on depression in Parkinson's disease: A randomized, double-blind, placebo-controlled study. Movement Disorders. October. 2010;25(14):2311-7. [pmid: 20740485].
238 Palm U, Keeser D, Schiller C, Fintescu Z, Reisinger E, Baghai TC, et al. Transcranial direct current stimulation in a patient with therapy-resistant major depression. World Journal of Biological Psychiatry. 2009;10(4 PART 2):632-5. [pmid: 19995213].
239 Pancheri P. Guide of pharmacological treatment of depression. Consensus Conference. Firenze. 24-25 September 1993. [Italian]. Rivista di Psichiatria. 1994;29(5):257-77.
240 Pantelis C, Barnes TRE. Drug strategies and treatment-resistant schizophrenia. Australian and New Zealand Journal of Psychiatry. 1996;30(1):20-37. [pmid: 8724325].
241 Parker G, Malhi G. Are atypical antipsychotic drugs also atypical antidepressants?. Australian and New Zealand Journal of Psychiatry. 2001;35(5):631-8. [pmid: 11551279].
242 Parsa MA, Simon M, Dubrow C, Ramirez LF, Meltzer HY. Psychiatric manifestations of olivo-ponto-cerebellar atrophy and treatment with clozapine. International Journal of Psychiatry in Medicine. 1993;23(2):149-56. [pmid: 8359997].
243 Partonen T, Sihvo S, Lonnqvist JK. Patients excluded from an antidepressant efficacy trial. Journal of Clinical Psychiatry. 1996;57(12):572-5. [pmid: 9010119].
244 Patkar AA, Peindl K, Mago R, Mannelli P, Masand PS. An open-label, rater-blinded, augmentation study of aripiprazole in treatment-resistant depression. Primary Care Companion to the Journal of Clinical Psychiatry. 2006;8(2):82-7.
245 Paul R, Schaaff N, Padberg F, Moller HJ, Frodl T. Comparison of racemic ketamine and S-ketamine in treatment-resistant major depression: Report of two cases. World Journal of Biological Psychiatry. 2009;10(3):241-4. [pmid: 19224412].
246 Peet M, Pratt JP. Lithium - Current status in psychiatric disorders. Drugs. 1993;46(1):7-17. [pmid: 7691509].
247 Pereira EAC, Wang S, Paterson DJ, Stein JF, Aziz TZ, Green AL. Sustained reduction of hypertension by deep brain stimulation. Journal of Clinical Neuroscience. January. 2010;17(1):124-7. [pmid: 19664927].
248 Petrides G, Braga RJ, Fink M, Mueller M, Knapp R, Husain M, et al. Seizure threshold in a large sample: Implications for stimulus dosing strategies in bilateral electroconvulsive therapy: A report from core. Journal of ECT. December. 2009;25(4):232-7. [pmid: 19972637].
249 Petrides G, Fink M. The ‘half-age’ stimulation strategy for ECT dosing. Convulsive Therapy. 1996;12(3):138-46. [pmid: 8872401].
250 Pierog JE, Kane KE, Kane BG, Donovan JW, Helmick T. Tricyclic antidepressant toxicity treated with massive sodium bicarbonate. American Journal of Emergency Medicine. November. 2009;27(9):1168.e3-.e7. [pmid: 19931778].
251 Post RM, Leverich GS, Altshuler L, Mikalauskas K. Lithium-discontinuation-induced refractoriness: Preliminary observations. American Journal of Psychiatry. 1992;149(12):1727-9. [pmid: 1443252].
252 Poutanen O, Huuhka K, Perko K. Severe anorexia nervosa, co-occurring major depressive disorder and electroconvulsive therapy as maintenance treatment: A case report. Cases Journal. December. 2009;2(12):9362. [pmid: 20062609].
253 Praharaj SK, Ram D, Arora M. Efficacy of high frequency (rapid) suprathreshold repetitive transcranial magnetic stimulation of right prefrontal cortex in bipolar mania: A randomized sham controlled study. Journal of Affective Disorders. October. 2009;117(3):146-50. [pmid: 19178948].
254 Pratap R, Farboud A, Patel H, Montgomery P. Vagal nerve stimulator implantation: The otolaryngologist's perspective. European Archives of Oto-Rhino-Laryngology. September. 2009;266(9):1455-9. [pmid: 19083010].
255 Price RB, Nock MK, Charney DS, Mathew SJ. Effects of Intravenous Ketamine on Explicit and Implicit Measures of Suicidality in Treatment-Resistant Depression. Biological Psychiatry. 01. Sep. 2009;66(5):522-6. [pmid: 19545857].
256 Proietti Cecchini A, Mea E, Tullo V, Curone M, Franzini A, Broggi G, et al. Vagus nerve stimulation in drug-resistant daily chronic migraine with depression: Preliminary data. Neurological Sciences. 2009;30(SUPPL. 1):S101-S4. [pmid: 19415436].
257 Prudic J, Sackeim HA. Electroconvulsive therapy suicide risk. Journal of Clinical Psychiatry. 1999;60(SUPPL. 2):104-10. [pmid: 10073397].
258 Puigdemont D, Portella MJ, Perez-Egea R, de Diego-Adelino J, Gironell A, Molet J, et al. Depressive Relapse After Initial Response to Subcallosal Cingulate Gyrus-Deep Brain Stimulation in a Patient with a Treatment-Resistant Depression: Electroconvulsive Therapy as a Feasible Strategy. Biological Psychiatry. 01. Sep. 2009;66(5):e11-e2. [pmid: 19427999].
259 Puzynski S, Koszewska I, Kalinowski A, Bogdanowicz E, Swiecicki L. Drug-resistance in endogenous depression. Part II. Refractoriness to antidepressants in the course of affective disorders. [Polish]. Psychiatria Polska. 1994;28(1):5-15. [pmid: 8190818].
260 Rabinak CA, Nirenberg MJ. Dopamine agonist withdrawal syndrome in parkinson disease. Archives of Neurology. January. 2010;67(1):58-63. [pmid: 20065130].
261 Rachid F, Golaz J, Bondolfi G, Bertschy G. Induction of a mixed depressive episode during rTMS treatment in a patient with refractory major depression. World Journal of Biological Psychiatry. 2006;7(4):261-4. [pmid: 17071547].
262 Radzik J, Zawadzka A, Leszek J, Mis M, Druszcz A. The course of meningioma of the olfactory groove in a patient with a 7-year long psychiatric history: Case study, and diagnostic difficulties. Psychogeriatria Polska. 2009;6(3):135-9.
263 Raes F, Sienaert P, Demyttenaere K, Peuskens J, Williams JMG, Hermans D. Overgeneral memory predicts stability of short-term outcome of electroconvulsive therapy for depression. Journal of ECT. 2008;24(1):81-3. [pmid: 18379339].
264 Rane LJ, Fekadu A, Wooderson S, Poon L, Markopoulou K, Cleare AJ. Discrepancy between subjective and objective severity in treatment-resistant depression: Prediction of treatment outcome. Journal of Psychiatric Research. November. 2010;44(15):1082-7. [pmid: 20471031].
265 Rasmussen KG. Electroconvulsive therapy versus transcranial magnetic stimulation for major depression: A review with recommendations for future research. Acta Neuropsychiatrica. 2008;20(6):291-4.
266 Rasmussen KG, Laurila DR, Brady BM, Lewis CL, Niemeyer KD, Sun NM, et al. Seizure length with sevoflurane and thiopental for induction of general anesthesia in electroconvulsive therapy: A randomized double-blind trial. Journal of ECT. 2006;22(4):240-2. [pmid: 17143153].
267 Rasmussen KG, Laurila DR, Brady BM, Lewis CL, Niemeyer KD, Sun NM, et al. Anesthesia outcomes in a randomized double-blind trial of sevoflurane and thiopental for induction of general anesthesia in electroconvulsive therapy. Journal of ECT. 2007;23(4):236-8. [pmid: 18090695].
268 Rasmussen KG, Mueller M, Knapp RG, Husain MM, Rummans TA, Sampson SM, et al. Antidepressant medication treatment failure does not predict lower remission with ECT for major depressive disorder: A report from the consortium for research in electroconvulsive therapy. J Clin Psychiatry. 2007;68(11):1701-6. [pmid: 18052563].
269 Reus VI. Rational polypharmacy in the treatment of mood disorders. Annals of Clinical Psychiatry. 1993;5(2):91-100. [pmid: 8102302].
270 Rohan M, Parow A, Stoll AL, Demopulos C, Friedman S, Dager S, et al. Low-field magnetic stimulation in bipolar depression using an MRI-based stimulator. American Journal of Psychiatry. 2004;161(1):93-8. [pmid: 14702256].
271 Rosa MA, Rosa MO, Belegarde IMT, Bueno CR, Fregni F. Recovery after ECT: comparison of propofol, etomidate and thiopental. Revista Brasileira de Psiquiatria. 2008;30(2):149-51. [pmid: 18470404].
272 Rosan TA, Mesones HL, Brengio F. Combined therapy with tricyclic and MAOI antidepressants in the treatment of resistant major depression. [Spanish]. Acta Psiquiatrica y Psicologica de America Latina. 1994;40(4):314-20. [pmid: 7484185].
273 Rosche J, Uhlmann C, Weber R. Changes of Coping Strategies in Patients with Therapy Refractory Epilepsy in the Course of a Ward Based Treatment with a Holistic Therapeutic Approach. [German]. PPmP Psychotherapie Psychosomatik Medizinische Psychologie. 2004;54(1):4-8.
274 Rosenberg O, Shoenfeld N, Kotler M, Dannon PN. Mood disorders in elderly population: Neurostimulative treatment possibilities. Recent Patents on CNS Drug Discovery. 2009;4(2):149-55. [pmid: 19519563].
275 Rosenberg O, Shoenfeld N, Zangen A, Kotler M, Dannon PN. Deep TMS in a resistant major depressive disorder: A brief report. Depression and Anxiety. May. 2010;27(5):465-9. [pmid: 20455247].
276 Rosenberg PB, Mehndiratta RB, Mehndiratta YP, Wamer A, Rosse RB, Balish M. Repetitive transcranial magnetic stimulation treatment of comorbid posttraumatic stress disorder and major depression. J Neuropsychiatry Clin Neurosci. Summer. 2002;14(3):270-6. [pmid: 12154150].
277 Rosenlicht NZ, Gerner RH. Systematic approach to the psychopharmacologic treatment of resistant depression. Annals of Clinical Psychiatry. 1990;2(1):57-65.
278 Rosenquist PB, McCall WV, Farah A, Reboussin DM. Effects of caffeine pretreatment on measures of seizure impact. Convulsive Therapy. 1994;10(2):181-5. [pmid: 8069645].
279 Rossi S, Ulivelli M, Malentacchi M, Greco G, Bartalini S, Borgogni P, et al. Effects of immunotherapy on motor cortex excitability in Stiff Person Syndrome. Journal of Neurology. February. 2010;257(2):281-5. [pmid: 19820984].
280 Roth RM, Jobst BC, Thadani VM, Gilbert KL, Roberts DW. New-onset obsessive-compulsive disorder following neurosurgery for medication-refractory seizure disorder. Epilepsy and Behavior. April. 2009;14(4):677-80. [pmid: 19435591].
281 Rucklidge JJ. Successful treatment of OCD with a micronutrient formula following partial response to Cognitive Behavioral Therapy (CBT): A case study. Journal of Anxiety Disorders. 2009;23(6):836-40. [pmid: 19329277].
282 Sackeim HA, Prudic J, Devanand DP, Nobler MS, Lisanby SH, Peyser S, et al. A prospective, randomized, double-blind comparison of bilateral and right unilateral electroconvulsive therapy at different stimulus intensities. Arch Gen Psychiatry. 2000;57(5):425-34. [pmid: 10807482].
283 Sackeim HA, Prudic J, Nobler MS, Fitzsimons L, Lisanby SH, Payne N, et al. Effects of pulse width and electrode placement on the efficacy and cognitive effects of electroconvulsive therapy. Brain Stimulation. 2008;1(2):71-83. [pmid: 19756236].
284 Sadrediny S, Molaeephard M, Mir-Ahmadi M. Sexual disorder improvement: A target or a way in treatment of fibromyalgia. A case report and brief review. Modern Rheumatology. February. 2010;20(1):74-6. [pmid: 19802653].
285 Saito S, Kadoi Y, Nara T, Sudo M, Obata H, Morita T, et al. The comparative effects of propofol versus thiopental on middle cerebral artery blood flow velocity during electroconvulsive therapy. Anesth Analg. 2000;91(6):1531-6. [pmid: 11094013].
286 Saitoh A, Yamaguchi K, Murasawa H, Kamei J. The approaches in the discovery of antidepressants using affective disorder models. [Japanese]. Japanese Journal of Neuropsychopharmacology. 2003;23(2):75-82. [pmid: 12762219].
287 Sajatovic M, Gyulai L, Calabrese JR, Thompson TR, Wilson BG, White R, et al. Maintenance treatment outcomes in older patients with bipolar I disorder. American Journal of Geriatric Psychiatry. 2005;13(4):305-11. [pmid: 15845756].
288 Sakkas P, Theleritis CG, Psarros C, Papadimitriou GN, Soldatos CR. Jacksonian seizure in a manic patient treated with rTMS. World Journal of Biological Psychiatry. 2008;9(2):159-60. [pmid: 18428081].
289 Saldana MT, Navarro A, Perez C, Masramon X, Rejas J. Patient-reported-outcomes in subjects with painful lumbar or cervical radiculopathy treated with pregabalin: Evidence from medical practice in primary care settings. Rheumatology International. June. 2010;30(8):1005-15. [pmid: 19798503].
290 Samaras N, Rossi G, Giannakopoulos P, Gold G. Vascular depression. An age-related mood disorder. European Geriatric Medicine. 2010;1(4):220-5.
291 Sampson SM, Rome JD, Rummans TA. Slow-frequency rTMS reduces fibromyalgia pain. Pain Med. Mar-Apr. 2006;7(2):115-8. [pmid: 16634724].
292 Santos MA, Hara C, Stumpf BLP, Rocha FL. Treatment-resistant depression: Review of pharmacologic antidepressant strategies. Jornal Brasileiro de Psiquiatria. 2006;55(3):232-42.
293 Santy PA, Bryant SG. Teaching clinical psychopharmacology on an inpatient psychiatric research center. Journal of Clinical Pharmacology. 1994;34(3):215-21. [pmid: 8021328].
294 Satterthwaite TD, Cristancho MA, Alici Y, Weiss D, O'Reardon JP. Electroconvulsive therapy in a 72-year-old woman with a history of Takotsubo cardiomyopathy: a case report and review of the literature. Brain Stimulation. October. 2009;2(4):238-40. [pmid: 20633423].
295 Schaffer A, Levitt AJ, Joffe RT. Mexiletine in treatment-resistant bipolar disorder. Journal of affective disorders. Jan. 2000;57(1-3):249-53. [pmid: 10708839].
296 Schiffer F, Teicher MH, Anderson C, Tomoda A, Polcari A, Navalta CP, et al. Determination of hemispheric emotional valence in individual subjects: A new approach with research and therapeutic implications. Behavioral and Brain Functions. 2007;3.
297 Schmidt EZ, Reininghaus B, Enzinger C, Ebner C, Hofmann P, Kapfhammer HP. Changes in brain metabolism after ECT-Positron emission tomography in the assessment of changes in glucose metabolism subsequent to electroconvulsive therapy - Lessons, limitations and future applications. Journal of Affective Disorders. 2008;106(1-2):203-8. [pmid: 17662472].
298 Schoenberg MR, Mash KM, Bharucha KJ, Francel PC, Scott JG. Deep brain stimulation parameters associated with neuropsychological changes in subthalamic nucleus stimulation for refractory Parkinson's disease. Stereotact Funct Neurosurg. 2008;86(6):337-44. [pmid: 18854660].
299 Schreiber S, Shalev A. Lithium augmentation for mianserine-resistant depression in the elderly. [Hebrew]. Harefuah. 1992;123(7-8).
300 Schutter DJLG, Martin Laman D, Van Honk J, Vergouwen AC, Frank Koerselman G. Partial clinical response to 2 weeks of 2 Hz repetitive transcranial magnetic stimulation to the right parietal cortex in depression. International Journal of Neuropsychopharmacology. June. 2009;12(5):643-50. [pmid: 18925985].
301 Scott MA, Shelton PS, Gattis W. Therapeutic options for treating major depression, and the role of venlafaxine. Pharmacotherapy. 1996;16(3 I):352-65. [pmid: 8726593].
302 Seethalakshmi R, Krishnamoorthy ES. Depression in epilepsy: Phenomenology, diagnosis and management. Epileptic Disorders. 2007;9(1):1-10. [pmid: 17307706].
303 Segawa K, Azuma H, Sato K, Yasuda T, Arahata K, Otsuki K, et al. Regional cerebral blood flow changes in depression after electroconvulsive therapy. Psychiatry Research Neuroimaging. 2006;147(2-3):135-43.
304 Seifritz E, Hemmeter U, Poldinger W. Lithium-augmentation at therapyfractious depressions. [German]. TW Neurologie Psychiatrie. 1994;8(4).
305 Serra M, Gasto C, Navarro V, Torres X, Blanch J, Masana G. Maintenance electroconvulsive therapy in elderly psychotic unipolar depression. Medicina Clinica. 2006;126(13):491-2. [pmid: 16624227].
306 Shabani A, Zolfigol F, Akbari M. Brief major depressive episode as an essential predictor of the Bipolar Spectrum Disorder. Journal of Research in Medical Sciences. 2009;14(1):29-35. [pmid: 21772858].
307 Shapira B, Newman ME, Gelfin Y, Lerer B. Blunted temperature and cortisol responses to ipsapirone in major depression: lack of enhancement by electroconvulsive therapy. Psychoneuroendocrinology. 2000;25(5):421-38. [pmid: 10818278].
308 Shapira NA, Verduin ML, DeGraw JD. Treatment of refractory major depression with tramadol monotherapy [2] (multiple letters). Journal of Clinical Psychiatry. 2001;62(3):205-6. [pmid: 11305709].
309 Sharma V. Loss of response to antidepressants and subsequent refractoriness: Diagnostic issues in a retrospective case series. Journal of affective disorders. 2001;64(1):99-106. [pmid: 11292524].
310 Sharma V, Persad E. Pharmacotherapy of rapid cycling bipolar disorder: A review. Lithium. 1994;5(3):117-25.
311 Shrestha S, Shrestha BR, Thapa C, Pradhan SN, Thapa R, Adhikari S. Comparative study of esmolol and labetalol to attenuate haemodynamic responses after electroconvulsive therapy. Kathmandu University Medical Journal. 2007;5(19):318-23.
312 Shulman KI, Herrmann N. Bipolar disorder in old age. Can Fam Physician. 1999;45:1229-37. [pmid: 10349067].
313 Sicard D. Current aspects of AIDS. [French]. Concours Medical. 1990;112(29):2665-8.
314 Sienaert P, Vansteelandt K, Demyttenaere K, Peuskens J. Ultra-brief pulse ECT in bipolar and unipolar depressive disorder: Differences in speed of response. Bipolar Disorders. 2009;11(4):418-24. [pmid: 19500095].
315 Simon NM, Kaufman RE, Hoge EA, Worthington JJ, Herlands NN, Owens ME, et al. Open-label support for duloxetine for the treatment of panic disorder. CNS Neuroscience and Therapeutics. Spring. 2009;15(1):19-23. [pmid: 19228176].
316 Simuni T, Sethi K. Nonmotor manifestations of Parkinson's disease. Annals of Neurology. 2008;64(Suppl. 2):S65-S80. [pmid: 19127582].
317 Singleton AH, Rosenquist PB, Kimball J, McCall WV. Cardiac rhythm disturbance in a depressed patient after implantation with a vagus nerve stimulator. Journal of ECT. September. 2009;25(3):195-7. [pmid: 19384253].
318 Sluzewska A, Samborski W, Sobieska M, Klein R, Bosmans E, Rybakowski JK. Serotonin antibodies in relation to immune activation in major depression. Human Psychopharmacology. 1997;12(5):453-8.
319 Sobhan T, Sobhan FZ, Feldman JM, Ryan WG. Medication options for treatment-resistant schizophrenia: Implications for global mental health financing. International Journal of Psychiatry in Clinical Practice. 2006;10(3):213-9.
320 Soekadar SR, Arfeller C, Rilk A, Plontke SK, Plewnia C. Theta burst stimulation in the treatment of incapacitating tinnitus accompanied by severe depression. CNS Spectrums. 2009;14(4):208-11. [pmid: 19407732].
321 Sokolov STH, Joffe RT. Practical guidelines for combination drug therapy of treatment-resistant depression. CNS Drugs. 1995;4(5):341-50.
322 Sood N, Treglia M, Obenchain RL, Dulisse B, Melfi CA, Croghan TW. Determinants of antidepressant treatment outcome. Am J Manag Care. 2000;6(12):1327-36. [pmid: 11151810].
323 Sperling W, Reulbach U, Bleich S, Padberg F, Kornhuber J, Mueck-Weymann M. Cardiac effects of vagus nerve stimulation in patients with major depression. Pharmacopsychiatry. 2010;43(1):7-11. [pmid: 20013552].
324 Srinivasan SP, Hall JM, Leo RJ. Vocal cord dysfunction arising from vagal nerve stimulator removal. American Journal of Psychiatry. December. 2009;166(12):1412-3. [pmid: 19952086].
325 Starkstein SE, Migliorelli R. ECT in a patient with a frontal craniotomy and residual meningioma. Journal of Neuropsychiatry and Clinical Neurosciences. 1993;5(4):428-30. [pmid: 8286942].
326 Stek ML, van der Wurff FB, Uitdehaag BMJ, Beekman ATF, Hoogendijk WJG. ECT in the treatment of depressed elderly: lessons from a terminated clinical trial. International Journal of Geriatric Psychiatry. 2007;22(10):1052-4. [pmid: 17457952].
327 Stern WM, Tormos JM, Press DZ, Pearlman C, Pascual-Leone A. Antidepressant effects of high and low frequency repetitive transcranial magnetic stimulation to the dorsolateral prefrontal cortex: a double-blind, randomized, placebo-controlled trial. J Neuropsychiatry Clin Neurosci. Spring. 2007;19(2):179-86. [pmid: 17431065].
328 Strain SL. Fluoxetine-initiated ovulatory cycles in two clomiphene-resistant women [7]. American Journal of Psychiatry. 1994;151(4).
329 Stuart S, Wright JH, Thase ME, Beck AT. Cognitive therapy with inpatients. General Hospital Psychiatry. 1997;19(1):42-50. [pmid: 9034811].
330 Stuppack Ch H, De Col C, Honeder M, Kurz M, Meise U, Whitworth A. Treatment strategies in depression - An Austrian survey. [German]. Neuropsychiatrie. 1998;12(2):91-7.
331 Suslow T. Estimating verbal intelligence in unipolar depression: Comparison of word definition and word recognition. Nordic Journal of Psychiatry. 2009;63(2):120-3. [pmid: 18985516].
332 Suzuki M, Kimura M, Okazaki M, Hara K, Hino K, Watanabe M, et al. Spike-wave stupor during treatment with paroxetine: A case report. [Japanese]. Journal of the Japan Epilepsy Society. 2007;25(1):10-5.
333 Swann AC. Mixed or dysphoric manic states: psychopathology and treatment. J Clin Psychiatry. 1995;56(3 SUPPL):6-10. [pmid: 7883742].
334 Swartz HA, Frank E. Psychotherapy for bipolar depression: a phase-specific treatment strategy?. Bipolar Disorders. 2001;3(1):11-22. [pmid: 11256459].
335 Swiecicki L. Efficacy of citalopram in more than maximal dose in drug-resistant depression. Case report. [Polish]. Psychiatria Polska. 2003;37(5):839-44. [pmid: 14631603].
336 Tahir N. Serotonin syndrome as a consequence of drug-resistant infections: An interaction between linezolid and citalopram. Journal of the American Medical Directors Association. 2004;5(2):111-3. [pmid: 14984623].
337 Takechi K, Abe T, Yorozuya T, Watanabe T, Nagaro T. Refractory hypotension during general anaesthesia caused by the long-term use of amoxapine. Anaesthesia and Intensive Care. September. 2010;38(5):965-6. [pmid: 20865899].
338 Taylor RS, Elston J. The use of surrogate outcomes in model-based cost-effectiveness analyses: a survey of UK Health Technology Assessment reports. Health Technology Assessment. 2009;13(8):iii-40.
339 Terry R. Vagus nerve stimulation: a proven therapy for treatment of epilepsy strives to improve efficacy and expand applications. Conference proceedings : . 2009;Annual International Conference of the IEEE Engineering in Medicine and Biology Society. IEEE Engineering in Medicine and Biology Society. Conference. 2009:4631-4.
340 Thase ME, Mallinger AG, McKnight D, Himmelhoch JM. Treatment of imipramine-resistant recurrent depression, IV: A double-blind crossover study of tranylcypromine for anergic bipolar depression. American Journal of Psychiatry. 1992;149(2):195-8. [pmid: 1734739].
341 Thompson C, Rodin I, Childs PA. Commentary on ‘The management of treatment-resistant affective disorder: Clinical perspectives’ [2]. Journal of Psychopharmacology. 1992;6(4):534-5.
342 Tolin DF, Frost RO, Steketee G. An open trial of cognitive-behavioral therapy for compulsive hoarding. Behaviour Research and Therapy. 2007;45(7):1461-70. [pmid: 17306221].
343 Tomruk NB, Saatcioglu O, Ugurlu E, Hacioglu M. ECT use in refractory obsessive-compulsive disorder. Klinik Psikofarmakoloji Bulteni. 2010;20(2):167-70.
344 Tourigny-Rivard MF. Treatment of depression in the elderly. Canadian Pharmaceutical Journal. 1985;118(6):286-7.
345 Tramontina JF, Andreazza AC, Kauer-Sant'Anna M, Stertz L, Goi J, Chiarani F, et al. Brain-derived neurotrophic factor serum levels before and after treatment for acute mania. Neuroscience Letters. 13. Mar. 2009;452(2):111-3. [pmid: 19383424].
346 Triezenberg D, Vachon D, Helmen J. How should you manage a depressed patient unresponsive to an SSRI?. Journal of Family Practice. 2006;55(12):1081-2+7. [pmid: 17137547].
347 Tsiouris JA, Cohen IL, Patti PJ, Korosh WM. Treatment of previously undiagnosed psychiatric disorders in persons with developmental disabilities decreased or eliminated self-injurious behavior. Journal of Clinical Psychiatry. 01. Sep. 2003;64(9):1081-90. [pmid: 14628984].
348 Tundo A, Salvati L, Busto G, Di Spigno D, Falcini R. Addition of cognitive-behavioral therapy for nonresponders to medication for obsessive-compulsive disorder: A naturalistic study. J Clin Psychiatry. 2007;68(10):1552-6. [pmid: 17960971].
349 Ulzen TP, Powers RE. A review of empirical evidence of somatic treatment options for the MI/DD population. Psychiatr Q. 2008;79(3):265-73. [pmid: 18726159].
350 Ungvari GS, Leung Siu K, Wai-Kwong T, Ng Fung S. The pharmacological treatment of catatonia: An overview. European Archives of Psychiatry and Clinical Neuroscience. 2001;251(SUPPL. 1):31-4.
351 Unutzer J. Late-life depression. New England Journal of Medicine. 2007;357(22):2269-76. [pmid: 18046030].
352 Uzun O. Lamotrigine as an augmentation agent in treatment-resistant obsessivecompulsive disorder: A case report. Journal of Psychopharmacology. March. 2010;24(3):425-7. [pmid: 19010977].
353 Uzun O, Ozdemir B. Aripiprazole as an augmentation agent in treatment-resistant body dysmorphic disorder. Clinical Drug Investigation. 2010;30(10):707-10. [pmid: 20701402].
354 Van Den Brink G. The therapy of a depressive man. Pharmacological reflections. [Dutch]. Pharmaceutisch Weekblad. 1999;134(35):1212-8.
355 Van Den Broek WW, Groenland THN, Mulder PGH, Kusuma A, Birkenhager TK, Pluijms EM, et al. Beta-blockers and electroconvulsive therapy: a review. Tijdschrift voor Psychiatrie. 2008;50(4):205-12. [pmid: 18398800].
356 Van Der Starre PJA, Lemmens HJM, Chandel A, Solvason HB, Brock-Utne JG. The effects of esmolol and labetalol on cerebral blood flow velocity during electroconvulsive therapy [6]. European Journal of Anaesthesiology. 2008;25(2):174-6. [pmid: 18251042].
357 Van Praag HM. Treatment of refractory primary depression. [Dutch]. Nederlands Tijdschrift voor Geneeskunde. 1997;141(28):1375-9. [pmid: 9380197].
358 Van Zijl DH, Gordon PC, James MF. The comparative effects of remifentanil or magnesium sulfate versus placebo on attenuating the hemodynamic responses after electroconvulsive therapy. Anesth Analg. 2005;101(6):1651-5. [pmid: 16301236].
359 Viikki M, Anttila S, Kampman O, Illi A, Huuhka M, Setala-Soikkeli E, et al. Vascular endothelial growth factor (VEGF) polymorphism is associated with treatment resistant depression. Neuroscience Letters. June. 2010;477(3):105-8. [pmid: 20417690].
360 Viikki M, Kampman O, Illi A, Setala-Soikkeli E, Anttila S, Huuhka M, et al. TPH1 218A/C polymorphism is associated with major depressive disorder and its treatment response. Neuroscience Letters. 01. Jan. 2010;468(1):80-4. [pmid: 19874868].
361 Villeneuve A. Duration of treatment by antidepressants. [French]. Encephale. 1992;18(SPEC. ISS. IV):517-20. [pmid: 1308848].
362 Vinar O. Tianeptine helps depressed patients resistant to reuptake inhibitors and/or IMAO. Homeostasis in Health and Disease. 1999;39(6):234-5.
363 Vishne T, Aronov S, Amiaz R, Etchin A, Grunhaus L. Remifentanil supplementation of propofol during electroconvulsive therapy: effect on seizure duration and cardiovascular stability. J ECT. 2005;21(4):235-8. [pmid: 16301884].
364 Wajima Z, Shiga T, Imanaga K, Inoue T. Prophylactic continuous administration of landiolol, a novel beta1 blocker, blunts hyperdynamic responses during electroconvulsive therapy without altering seizure activity. International Journal of Psychiatry in Clinical Practice. 2010;14(2):132-6.
365 Wajima Z, Yoshikawa T, Ogura A, Imanaga K, Shiga T, Inoue T, et al. The effects of diltiazem on hemodynamics and seizure duration during electroconvulsive therapy. Anesth Analg. 2001;92(5):1327-30. [pmid: 11323371].
366 Walder B, Seeck M, Tramer MR. Propfol versus methohexital for electroconvulsive therapy: a meta-analysis. Journal of Neurosurgical Anesthesiology. 2001;13(2):93-8. [pmid: 11294464].
367 Walker WR, Freeman RF, Christensen DK. Restricting Environmental Stimulation (REST) to enhance cognitive behavioral treatment for obsessive compulsive disorder with schizotypal personality disorder. Behavior Therapy. 1994;25(4):709-19.
368 Wang XM, Yang DB, Yu YF, Huang H, Zhao XQ. A controlled study of the treatment of repetitive transcranial magnetic stimulation in patients with major depression. Chinese Journal of Clinical Rehabilitation. 2004:1770-1.
369 Wang YT, Yan F, Li ZQ, Du BG, Wang P, Zhang ZH. Effect of psychological intervention on in psychic anxiety family members of patients receiving modified electroconvulsive therapy. Chinese Journal of Clinical Rehabilitation. 2004;8(24):4956-7.
370 Warnell RL, Swartz CM, Thomson A. Propofol interruption of ECT seizure to reduce side-effects: A pilot study. Psychiatry Research. 30. Jan. 2010;175(1-2):184-5. [pmid: 19892408].
371 Watson K, Summers KM. Depression in patients with heart failure: Clinical implications and management. Pharmacotherapy. 2009;29(1):49-63. [pmid: 19113796].
372 Weder ND, Muralee S, Penland H, Tampi RR. Catatonia: A review. Annals of Clinical Psychiatry. 2008;20(2):97-107. [pmid: 18568581].
373 Wehr TA. Manipulations of sleep and phototherapy: Nonpharmacological alternatives in the treatment of depression. Clinical Neuropharmacology. 1990;13(SUPPL. 1):S54-S65. [pmid: 2199036].
374 Weller EB, Weller RA. Treatment options in the management of adolescent depression. Journal of Affective Disorders. 2000;61(Suppl. 1):S23-S8.
375 Wells A, Welford M, Fraser J, King P, Mendel E, Wisely J, et al. Chronic PTSD treated with metacognitive therapy: an open trial. Cognitive and Behavioral Practice. 2008;15(1):85-92.
376 Wiethoff K, Bauer M, Baghai T, Heinz A, Adli M. Algorithms in the treatment of depression - The German Algorithm Project (“Berliner Algorithmusprojekt”). [German]. Nervenheilkunde. 2005;24(5):381-7.
377 Wilson K. Vascular disease, depression and cognitive impairment. Encephale. 2008;34(Suppl.2):S50-S4. [pmid: 18675001].
378 Wolkowitz OM. Rational polypharmacy in schizophrenia. Annals of Clinical Psychiatry. 1993;5(2):79-90. [pmid: 8348207].
379 Wong ICK, Tavernor SJ, Tavernor RME. Psychiatric adverse effects of anticonvulsant drugs: Incidence and therapeutic implications. CNS Drugs. 1997;8(6):492-509.
380 Wu CC, Tsai CH, Lu MK, Chen CM, Shen WC, Su KP. Theta-burst repetitive transcranial magnetic stimulation for treatment-resistant obsessive-compulsive disorder with concomitant depression. Journal of Clinical Psychiatry. April. 2010;71(4):504-6. [pmid: 20409448].
381 Wu L, Zou H, Zhou Q, Liu Z, Cheng B. Preemptive analgesia with butorphanol in psychotic patients following modified electroconvulsive therapy: A randomized controlled trial. Neural Regeneration Research. 2008;3(1):75-8.
382 Yamamoto S, Miyamoto T, Morita N, Yasuda M. Depressive disorders preceding temporal lobe epilepsy. Epilepsy Research. 2002;49(2):153-6. [pmid: 12049803].
383 Yonkers KA, Wisner KL, Stowe Z, Leibenluft E, Cohen L, Miller L, et al. Management of bipolar disorder during pregnancy and the postpartum period. Am J Psychiatry. 2004;161(4):608-20. [pmid: 15056503].
384 Zacest A, Anderson VC, Burchiel KJ. The glass half empty or half full - How effective are long-term intrathecal opioids in post-herpetic neuralgia? a case series and review of the literature. Neuromodulation. July. 2009;12(3):219-23.
385 Zarate CA Jr, Singh JB, Carlson PJ, Brutsche NE, Ameli R, Luckenbaugh DA, et al. A randomized trial of an N-methyl-D-aspartate antagonist in treatment-resistant major depression. Arch Gen Psychiatry. 2006;63(8):856-64. [pmid: 16894061].
386 Zarkowski P, Navarro R, Pavlicova M, George MS, Avery D. The effect of daily prefrontal repetitive transcranial magnetic stimulation over several weeks on resting motor threshold. Brain Stimulation. July. 2009;2(3):163-7. [pmid: 20161065].
387 Zhang Y, White PF, Thornton L, Perdue L, Downing M. The use of nicardipine for electroconvulsive therapy: a dose-ranging study. Anesth Analg. Feb. 2005;100(2):378-81. [pmid: 15673861].
388 Ziegler B. Antidepressant agents: Which drug is the best for the individual patient?. [German]. Therapiewoche. 1993;43(51-52):2752-5.
389 Zinetti J, Tenneze L, Rabus MT, Dare F. Addition of lithium carbonate and antidepressant drugs in resistant depression of elderly. [French]. Revue de Geriatrie. 1996;21(6).
390 Zvara DA, Brooker RF, McCall WV, Foreman AS, Hewitt C, Murphy BA, et al. The effect of esmolol on ST-segment depression and arrhythmias after electroconvulsive therapy. Convuls Ther. Sep. 1997;13(3):165-74. [pmid: 9342132].

## PsychInfo Database = 589 articles (excluding duplicates)

1 Mania Due to Ziprasidone Augmentation of a Selective Serotonin Reuptake Inhibitor. Primary Psychiatry. 01. 2004;11(1):17-8.
2 Visual hallucinations due to the addition of riluzole to memantine and bupropion. Primary Psychiatry. 06. 2006;13(6):25-6.
3 aan het Rot M, Collins KA, Murrough JW, Perez AM, Reich DL, Charney DS, et al. Safety and efficacy of repeated-dose intravenous ketamine for treatment-resistant depression. Biological Psychiatry. 2010;67(2):139-45. [pmid: 19897179].
4 Abarbanel JM, Lemberg T, Yaroslavski U, Grisaru N, et al. Electrophysiological responses to transcranial magnetic stimulation in depression and schizophrenia. Biological Psychiatry. Jul. 1996. 1996;40(2):148-50. [pmid: 8793047].
5 Abraham G, Milev R, Lazowski L, Jokic R, du Toit R, Lowe A. Repetitive transcranial magnetic stimulation for treatment of elderly patients with depression--An open label trial. Neuropsychiatric Disease and Treatment. 2007;3(6):919-24. [pmid: 19300628].
6 Abramowitz MZ, Lichtenberg P, Marcus EL, Shapira B. Treating a Holocaust survivor without addressing the Holocaust: a case report. Clinical Gerontologist. 1994;14(3):75-80.
7 Achiffer F, Stinchfield Z, Pascual-Leone A. Prediction of clinical response to transcranial magnetic stimulation for depression by baseline lateral visual-field stimulation. Neuropsychiatry, Neuropsychology, & Behavioral Neurology. Mar. 2002;15(1):18-27.
8 Alonso-Navarro H, Jiménez-Jiménez FJ, Pilo-de-la-Fuente B, Plaza-Nieto JF. Panic attack-like episodes possibly associated with ropinirole. Clinical neuropharmacology. 2009;32(4):237-8. [pmid: 19644237].
9 Amiaz R, Stein O, Dannon PN, Grunhaus L, Schreiber S. Resolution of treatment-refractory depression with naltrexone augmentation of paroxetine: A case report. Psychopharmacology. Apr. 1999;143(4):433-4. [pmid: 10367562].
10 Amsterdam JD. A 36-year-old man with a history of non-response to multiple medications: trials of various pharmacologic combinations may be necessary to find the correct treatment in some cases of resistant depression. Psychiatric Annals. Mar. 2004;34(3):180-1.
11 Amsterdam JD, Chopra M. Monoamine oxidase inhibitors revisited. Psychiatric Annals. 2001;31(6):361-70.
12 Anderson B, Mishory A, Nahas Z, Borckardt JJ, Yamanaka K, Rastogi K, et al. Tolerability and safety of high daily doses of repetitive transcranial magnetic stimulation in healthy young men. Journal of ECT. 2006;22(1):49-53. [pmid: 16633208].
13 Anderson BS, Kavanagh K, Borckardt JJ, Nahas ZH, Kose S, Lisanby SH, et al. Decreasing procedural pain over time of left prefrontal rTMS for depression: Initial results from the open-label phase of a multisite trial (OPT-TMS). Brain Stimulation. 2009;2(2):88-92. [pmid: 20161310].
14 Anderson IM, Sarsfield A, Haddad PM. Efficacy, safety and tolerability of quetiapine augmentation in treatment resistant depression: An open-label, pilot study. Journal of Affective Disorders. 09. 2009;117(1):116-9. [pmid: 19171384].
15 Antal A, Terney D, Kühnl S, Paulus W. Anodal transcranial direct current stimulation of the motor cortex ameliorates chronic pain and reduces short intracortical inhibition. Journal of Pain and Symptom Management. 2010;39(5):890-903. [pmid: 20471549].
16 Anwar N, Brakoulias V. Safety of electroconvulsive therapy after subdural haemorrhage. Australian and New Zealand Journal of Psychiatry. 2010;44(3).
17 Argyropoulos SV, Wheeler A, Nutt DJ. A case of reversal of treatment-resistant depression after almost 30 years of symptoms. International Journal of Psychiatry in Clinical Practice. 12. 1999;3(4):289-91.
18 Arias L, O'Brien JJ, Kimball JN. Electroconvulsive therapy- and succinylcholine-related asystole. The Journal of ECT. 2009;25(2).
19 Arul-Anandam AP, Loo C, Martin D, Mitchell PB. Chronic neuropathic pain alleviation after transcranial direct current stimulation to the dorsolateral prefrontal cortex. Brain Stimulation. 2009;2(3):149-51. [pmid: 20633414].
20 Arul-Anandam AP, Loo C, Mitchell P. Induction of hypomanic episode with transcranial direct current stimulation. The Journal of ECT. 2010;26(1):68-9. [pmid: 19483641].
21 Ashton AK. A case report of high-dose transdermal selegiline in the treatment of major depressive disorder. Annals of Clinical Psychiatry. 2009;21(1):51-2. [pmid: 19239833].
22 Baeken C, Leyman L, De Raedt R, Vanderhasselt MA, D'Haenen H. Lack of impact of repetitive high frequency transcranial magnetic stimulation on mood in healthy female subjects. Journal of Affective Disorders. Jan. 2006;90(1):63-6. [pmid: 16325919].
23 Baghai TC, di Michele F, Schüle C, Eser D, Zwanzger P, Pasini A, et al. Plasma concentrations of neuroactive steroids before and after electroconvulsive therapy in major depression. Neuropsychopharmacology. Jun. 2005;30(6):1181-6. [pmid: 15702138].
24 Bajbouj M, Luborzewski A, Danker-Hopfe H, Lang UE. Motor cortical excitability in depressive patients after electroconvulsive therapy and repetitive transcranial magnetic stimulation. Journal of ECT. Dec. 2005;21(4):243-5. [pmid: 16301886].
25 Bannan N. Multimodal therapy of treatment resistant depression: A study and analysis. International Journal of Psychiatry in Medicine. 2005;35(1):27-39. [pmid: 15977943].
26 Bär KJ, Ebert A, Boettger MK, Merz S, Kiehntopf M, Jochum T, et al. Is successful electroconvulsive therapy related to stimulation of the vagal system?. Journal of Affective Disorders. 2010;125(1-3):323-9. [pmid: 20202688].
27 Barak Y, Suholitsky H, Noy S. Moclobemide treatment of resistant depression in a patient with vascular dementia. Human Psychopharmacology: Clinical and Experimental. 01. 1996;11(1):67-8.
28 Barbee JG, Conrad EJ, Jamhour NJ. Aripiprazole Augmentation in Treatment-Resistant Depression. Annals of Clinical Psychiatry. 10. 2004;16(4):189-94. [pmid: 15702566].
29 Barbosa L, Berk M, Vorster M. A double-blind, randomized, placebo-controlled trial of augmentation with lamotrigine or placebo in patients concomitantly treated with fluoxetine for resistant major depressive episodes. Journal of Clinical Psychiatry. 04. 2003;64(4):403-7. [pmid: 12716240].
30 Bares M, Brunovsky M, Kopecek M, Novak T, Stopkova P, Kozeny J, et al. Early reduction in prefrontal theta QEEG cordance value predicts response to venlafaxine treatment in patients with resistant depressive disorder. European Psychiatry. 08. 2008;23(5):350-5. [pmid: 18450430].
31 Bares M, Kopecek M, Novak T, Stopkova P, Sos P, Kozeny J, et al. Low frequency (1-Hz), right prefrontal repetitive transcranial magnetic stimulation (rTMS) compared with venlafaxine ER in the treatment of resistant depression: A double-blind, single-centre, randomized study. Journal of Affective Disorders. 11. 2009;118(1):94-100. [pmid: 19249105].
32 Bauer M, Bschor T, Kunz D, Berghöfer A, Ströhle A, Müller-Oerlinghausen B. Double-blind, placebo-controlled trial of the use of lithium to augment antidepressant medication in continuation treatment of unipolar major depression. The American Journal of Psychiatry. 09. 2000;157(9):1429-35. [pmid: 10964859].
33 Bauer M, Hellweg R, Baumgartner A. Fluoxetine-induced akathisia does not reappear after switch to paroxetine. Journal of Clinical Psychiatry. 12. 1996;57(12):593-4. [pmid: 9010125].
34 Baumann P, Broly F, Kosel M, Eap CB. Ultrarapid metabolism of clomipramine in a therapy-resistant depressive patient, as confirmed by CYP2 D6 genotyping. Pharmacopsychiatry. 03. 1998;31(2):72. [pmid: 9562213].
35 Bayless JD, McCormick LM, Brumm MC, Espe-Pfeifer PB, Long JJ, Lewis JL. Pre- and post-electroconvulsive therapy multidomain cognitive assessment in psychotic depression: Relationship to premorbid abilities and symptom improvement. The Journal of ECT. 2010;26(1):47-52. [pmid: 19710624].
36 Bech P, Olsen LRk, Jarløv N, Hammer M, Schütze T, Breum L. A case of sequential anti-stress medication in a patient with major depression resistant to amine-reuptake inhibitors. Acta Psychiatrica Scandinavica. 07. 1999;100(1):76-8. [pmid: 10442443].
37 Beck S, Richardson SP, Shamim EA, Dang N, Schubert M, Hallett M. Short intracortical and surround inhibition are selectively reduced during movement initiation in focal hand dystonia. Journal of Neuroscience. Oct. 2008;28(41):10363-9. [pmid: 18842895].
38 Bell C, Wilson S, Nutt DJ. Pindolol augmentation of sertraline in resistant depression and its effect on sleep. Journal of Psychopharmacology. 1998;12(1):105-7. [pmid: 9584976].
39 Bergmann TO, Mölle M, Marshall L, Kaya-Yildiz L, Born J, Roman Siebner H. A local signature of LTP- and LTD-like plasticity in human NREM sleep. European Journal of Neuroscience. May. 2008;27(9):2241-9. [pmid: 18445215].
40 Bernardi S, Pallanti S. Successful duloxetine treatment of a binge eating disorder: A case report. Journal of Psychopharmacology. 2010;24(8):1269-72. [pmid: 19010975].
41 Bernik MrA, Corregiari FbM, Braun IMr. Panic attacks in the differential diagnosis and treatment of resistant epilepsy. Depression and Anxiety. 2002;15(4):190-2. [pmid: 12112726].
42 Bertschy G, Ragama-Pardos E, Aït-Ameur A, Muscionico M, Favre S, Roth L. Lithium augmentation in venlafaxine non-responders: An open study. European Psychiatry. 10. 2003;18(6):314-7. [pmid: 14611927].
43 Bewernick BH, Hurlemann R, Matusch A, Kayser S, Grubert C, Hadrysiewicz B, et al. Nucleus accumbens deep brain stimulation decreases ratings of depression and anxiety in treatment-resistant depression. Biological Psychiatry. 2010;67(2):110-6. [pmid: 19914605].
44 Birkenhäger TK, van den Broek WW, Fekkes D, Mulder PG, Moleman P, Bruijn JA. Lithium addition in antidepressant-resistant depression: Effects on platelet 5-HT, plasma 5-HT and plasma 5-HIAA concentration. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 06. 2007;31(5):1084-8. [pmid: 17467132].
45 Birkenhäger TK, Pluijms EM, Ju MR, Mulder PG, van den Broek WW. Influence of age on the efficacy of electroconvulsive therapy in major depression: A retrospective study. Journal of Affective Disorders. 2010;126(1-2):257-61. [pmid: 20303601].
46 Birkenhäger TK, van den Broek WW, Wijkstra J, Bruijn JA, van Os E, Boks M, et al. Treatment of unipolar psychotic depression: An open study of lithium addition in refractory psychotic depression. Journal of Clinical Psychopharmacology. 2009;29(5):513-5. [pmid: 19745662].
47 Birmaher B, Waterman GS, Ryan ND, Perel J, McNabb J, Balach L, et al. Randomized, controlled trial of amitriptyline versus placebo for adolescents with ‘treatment-resistant’ major depression. Journal of the American Academy of Child & Adolescent Psychiatry. 05. 1998;37(5):527-35. [pmid: 9585655].
48 Bishop J, Lane RC. Psychodynamic treatment of a case of grief superimposed on melancholia. Clinical Case Studies. Jan. 2003;2(1):3-19.
49 Black W, Hoey P, Mayze T. Modafinil use in patients with a primary psychiatric illness. Australian and New Zealand Journal of Psychiatry. 2010;44(6):583-4. [pmid: 20482418].
50 Blazer DG. Late life affective disorders. Archives of Gerontology and Geriatrics. 1998;1996(6):43-7.
51 Bliem B, Müller-Dahlhaus JFM, Dinse HR, Ziemann U. Homeostatic metaplasticity in human somatosensory cortex. Journal of Cognitive Neuroscience. Aug. 2008;20(8):1517-28. [pmid: 18303976].
52 Bloch Y, Grisaru N, Hard EV, Beitler G, Faivel N, Ratzoni G, et al. Repetitive transcranial magnetic stimulation in the treatment of depression in adolescents: An open-label study. Journal of ECT. Jun. 2008;24(2):153-9.
53 Blumer D. Antidepressant and double antidepressant treatment for the affective disorder of epilepsy. Journal of Clinical Psychiatry. 01. 1997;58(1):3-11. [pmid: 9055830].
54 Bodani M, Sheehan B, Philpot M. The use of dexamethasone in elderly patients with antidepressant-resistant depressive illness. Journal of Psychopharmacology. 1999;13(2):196-7. [pmid: 10475727].
55 Boggio PS, Bermpohl F, Vergara AO, Muniz ALCR, Nahas FH, Leme PB, et al. Go-no-go task performance improvement after anodal transcranial DC stimulation of the left dorsolateral prefrontal cortex in major depression. Journal of Affective Disorders. Aug. 2007;101(1):91-8. [pmid: 17166593].
56 Bonvicini C, Minelli A, Scassellati C, Bortolomasi M, Segala M, Sartori R, et al. Serotonin transporter gene polymorphisms and treatment-resistant depression. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 2010;34(6):934-9. [pmid: 20450949].
57 Bor J, Brunelin J, Rivet A, d'Amato T, Poulet E, Saoud M, et al. Effects of theta burst stimulation on glutamate levels in a patient with negative symptoms of schizophrenia. Schizophrenia Research. 2009;111(1-3):196-7. [pmid: 19339158].
58 Borckardt JJ, Anderson B, Kozel FA, Nahas Z, Smith AR, Thomas KJ, et al. Acute and long-term VNS effects on pain perception in a case of treatment-resistant depression. Neurocase. Aug. 2006;12(4):216-20. [pmid: 17000590].
59 Borckardt JJ, Reeves ST, Weinstein M, Smith AR, Shelley N, Kozel FA, et al. Significant analgesic effects of one session of postoperative left prefrontal cortex repetitive transcranial magnetic stimulation: A replication study. Brain Stimulation. Apr. 2008;1(2):122-7. [pmid: 19759838].
60 Borckardt JJ, Smith AR, Reeves ST, Weinstein M, Kozel FA, Nahas Z, et al. Fifteen minutes of left prefrontal repetitive transcranial magnetic stimulation acutely increases thermal pain thresholds in healthy adults. Pain Research & Management. Win. 2007;12(4):287-90. [pmid: 18080048].
61 Borroni P, Montagna M, Cerri G, Baldissera F. Bilateral motor resonance evoked by observation of a one-hand movement: Role of the primary motor cortex. European Journal of Neuroscience. Oct. 2008;28(7):1427-35. [pmid: 18973569].
62 Borson S, Raskind M. Antidepressant-resistant depression in the elderly. Journal of the American Geriatrics Society. Mar. 1986;34(3):245-7. [pmid: 3950294].
63 Bottonari KA, Roberts JE, Thomas SN, Read JP. Stop thinking and start doing: switching from cognitive therapy to behavioral activation in a case of chronic treatment-resistant depression. Cognitive and Behavioral Practice. Nov. 2008;15(4):376-86.
64 Boutros NN, Miano AP, Hoffman RE, Berman RM. EEG monitoring in depressed patients undergoing repetitive transcranial magnetic stimulation. Journal of Neuropsychiatry & Clinical Neurosciences. Spr. 2001;13(2):197-205. [pmid: 11449026].
65 Bowman ES, Coons PM. The use of electroconvulsive therapy in patients with dissociative disorders. Journal of Nervous and Mental Disease. Aug. 1992;180(8):524-8. [pmid: 1500935].
66 Boylan LS, Flint LA, Labovitz DL, Jackson SC, Starner K, Devinsky O. Depression but not seizure frequency predicts quality of life in treatment-resistant epilepsy. Neurology. 01. 2004;62(2):258-61. [pmid: 14745064].
67 Bramanti P, Grugno R, Vitetta A, Di Bella P, Muscará N, Nappi G. Migraine with and without aura: electrophysiological and functional neuroimaging evidence. Functional Neurology. Jan-Mar. 2005;20(1):29-32. [pmid: 15948565].
68 Brambilla P, Perez J, Monchieri S, Rossini PM, Bonato C. Transient improvement of tardive dyskinesia induced with rTMS. Neurology. Oct. 2003;61(8):1155. [pmid: 14581693].
69 Brent D, Emslie G, Clarke G, Wagner KD, Asarnow JR, Keller M, et al. Switching to another SSRI or to venlafaxine with or without cognitive behavioral therapy for adolescents with SSRI-resistant depression: The TORDIA randomized controlled trial. Journal of the American Medical Association. Feb. 2008;299(8):901-13. [pmid: 18314433].
70 Brent DA, Emslie GJ, Clarke GN, Asarnow J, Spirito A, Ritz L, et al. Predictors of spontaneous and systematically assessed suicidal adverse events in the treatment of SSRI-resistant depression in adolescents (TORDIA) study. The American Journal of Psychiatry. 04. 2009;166(4):418-26. [pmid: 19223438].
71 Brody AL, Saxena S, Fairbanks LA, Alborzian S, Demaree HA, Maidment KM, et al. Personality changes in adult subjects with major depressive disorder or obsessive-compulsive disorder treated with paroxetine. Journal of Clinical Psychiatry. 05. 2000;61(5):349-55. [pmid: 10847309].
72 Brunelin J, Maklouf WB, Nicolas A, Saoud M, Poulet E. Successful switch to maintenance rTMS after maintenance ECT in refractory bipolar disorder. Brain Stimulation. 2010;3(4):238-9. [pmid: 20965454].
73 Brunoni AR, Teng CT, Correa C, Imamura M, Brasil-Neto JP, Boechat R, et al. Neuromodulation approaches for the treatment of major depression: Challenges and recommendations from a working group meeting. Arquivos de Neuro-Psiquiatria. 2010;68(3):433-51. [pmid: 20602051].
74 Busch AM, Uebelacker LA, Kalibatseva Z, Miller IW. Measuring homework completion in behavioral activation. Behavior Modification. 2010;34(4):310-29. [pmid: 20562324].
75 Callahan RJ. The impact of thought field therapy on heart rate variability. Journal of Clinical Psychology. Oct. 2001;57(10):1153-70. [pmid: 11526602].
76 Cameron PM. Psychodynamic psychotherapy for the depressive syndrome. Psychiatric Journal of the University of Ottawa. Jun. 1989;14(2):397-402. [pmid: 2668995].
77 Camprubi ME, Puri BK. The treatment of refractory depression using paroxetine with lithium augmentation. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 05. 1995;19(3):515-7. [pmid: 7624502].
78 Carberry H. Psychological methods for helping the angry, resistant and negative patient. Cognitive Rehabilitation. Jul-Aug. 1983;1(4):4-5.
79 Cardoso EF, Fregni F, Maia FM, Boggio PS, Myczkowski ML, Coracini K, et al. rTMS treatment for depression in Parkinson's disease increases BOLD responses in the left prefrontal cortex. International Journal of Neuropsychopharmacology. Mar. 2008;11(2):173-83. [pmid: 17708780].
80 Carey JR, Evans CD, Anderson DC, Bhatt E, Nagpal A, Kimberley TJ, et al. Safety of 6-Hz primed low-frequency rTMS in stroke. Neurorehabilitation & Neural Repair. Mar-Apr. 2008;22(2):185-92. [pmid: 17876070].
81 Carpenter LL, Milosavljevic N, Schecter JM, Tyrka AR, Price LH. Augmentation With Open-Label Atomoxetine for Partial or Nonresponse to Antidepressants. Journal of Clinical Psychiatry. 10. 2005;66(10):1234-8. [pmid: 16259536].
82 Carpenter LL, Moreno FA, Kling MA, Anderson GM, Regenold WT, Labiner DM, et al. Effect of vagus nerve stimulation on cerebrospinal fluid monoamine metabolites, norepinephrine, and gamma-aminobutyric acid concentrations in depressed patients. Biological Psychiatry. Sep. 2004;56(6):418-26. [pmid: 15364040].
83 Carty JA. An examination of the relative effectiveness of three cognitive behavioral group treatments for depression in an Australian treatment-resistant population. Dissertation Abstracts International: Section B: The Sciences and Engineering. Jul. 2001;62(1):539.
84 Carvalho AF, Nunes-Neto PR, Cavalcante JL, Lima MCO. Amisulpride augmentation after the failure of citalopram for depression: A case report. Journal of Clinical Pharmacy and Therapeutics. 02. 2007;32(1):97-9. [pmid: 17286793].
85 Carvalho LA, Garner BA, Dew T, Fazakerley H, Pariante CM. Antidepressants, but not antipsychotics, modulate GR function in human whole blood: An insight into molecular mechanisms. European Neuropsychopharmacology. 2010;20(6):379-87. [pmid: 20231081].
86 Casamassima F, Lattanzi L, Perlis RH, Fratta S, Litta A, Longobardi A, et al. Efficacy of electroconvulsive therapy in Fahr disease associated with bipolar psychotic disorder: A Case Report. The Journal of ECT. 2009;25(3):213-5. [pmid: 19252444].
87 Cassano P, Lattanzi L, Fava M, Navari S, Battistini G, Abelli M, et al. Ropinirole in Treatment-Resistant Depression: A 16-Week Pilot Study. The Canadian Journal of Psychiatry. La Revue canadienne de psychiatrie. 05. 2005;50(6):357-60.
88 Cassano P, Lattanzi L, Soldani F, Navari S, Battistini G, Gemignani A, et al. Pramipexole in Treatment-Resistant Depression: An Extended Follow-Up. Depression and Anxiety. 2004;20(3):131-8. [pmid: 15549689].
89 Catafau AM, Perez V, Gironell A, Martin JC, Kulisevsky J, Estorch M, et al. SPECT mapping of cerebral activity changes induced by repetitive transcranial magnetic stimulation in depressed patients: A pilot study. Psychiatry Res: Neuroimaging. May. 2001;106(3):151-60.
90 Cavanagh J, Patterson J, Pimlott S, Dewar D, Eersels J, Dempsey MF, et al. Serotonin Transporter Residual Availability During Long-Term Antidepressant Therapy Does Not Differentiate Responder and Nonresponder Unipolar Patients. Biological Psychiatry. 02. 2006;59(4):301-8. [pmid: 16197922].
91 Chanpattana W, Kramer BA, Kunigiri G, Gangadhar BN, Kitphati R, Andrade C. A survey of the practice of electroconvulsive therapy in Asia. The Journal of ECT. 2010;26(1):5-10. [pmid: 19444137].
92 Chemtob CM, Novaco RW, Hamada RS, Gross DM. Cognitive-behavioral treatment for severe anger in posttraumatic stress disorder. Journal of Consulting and Clinical Psychology. Feb. 1997;65(1):184-9. [pmid: 9103748].
93 Chouinard G, Steiner W. A case of mania induced by high-dose fluoxetine treatment. The American Journal of Psychiatry. 05. 1986;143(5):686. [pmid: 3485926].
94 Chung JPY, Yim PHW, Dunn ELW. Clinical and treatment characteristics of Chinese patients undergoing electroconvulsive therapy in an acute psychiatric unit in Hong Kong. Hong Kong Journal of Psychiatry. 2009;19(4):150-4.
95 Cohen D. Should the use of selective serotonin reuptake inhibitors in child and adolescent depression be banned?. Psychotherapy and Psychosomatics. Dec. 2006;76(1):5-14. [pmid: 17170559].
96 Cohen H, Kaplan Z, Kotler M, Kouperman I, Moisa R, Grisaru N. Repetitive transcranial magnetic stimulation of the right dorsolateral prefrontal cortex in posttraumatic stress disorder: a double-blind, placebo-controlled study. American Journal of Psychiatry. Mar. 2004;161(3):515-24. [pmid: 14992978].
97 Cohen MX, Axmacher N, Lenartz D, Elger CE, Sturm V, Schlaepfer TE. Nuclei accumbens phase synchrony predicts decision-making reversals following negative feedback. The Journal of Neuroscience. 2009;29(23):7591-8. [pmid: 19515927].
98 Conca A, Hrubos W, Di Pauli J, König P, Hausmann A. ECT response after relapse during continuation repetitive transcranial magnetic stimulation A case report. European Psychiatry. Apr. 2004;19(2):118-9. [pmid: 15051113].
99 Conca A, König P, Hausmann A. Transcranial magnetic stimulation induces ‘pseudoabsence seizure’. Acta Psychiatrica Scandinavica. Mar. 2000;101(3):246-8. [pmid: 10721875].
100 Conca A, Peschina W, König P, Fritzsche H, Hausmann A. Effect of chronic repetitive transcranial magnetic stimulation on regional cerebral blood flow and regional cerebral glucose uptake in drug treatment-resistant depressives: A brief report. Neuropsychobiology. Jan. 2002;45(1):27-31. [pmid: 11803238].
101 Conca A, Swoboda E, König P, Koppi S, Beraus W, Künz A, et al. Clinical impacts of single transcranial magnetic stimulation (sTMS) as an add-on therapy in severely depressed patients under SSRI treatment. Hum Psychopharmacol: Clinical and Experimental. Aug. 2000;15(6):429-38.
102 Conus P, Bondolfi G, Eap CB, Macciardi F. Pharmacokinetic fluvoxamine-clomipramine interaction with favorable therapeutic consequences in therapy-resistant depressive patient. Pharmacopsychiatry. 05. 1996;29(3):108-10. [pmid: 8738315].
103 Cooke RG, Levitan RD. Tryptophan for refractory bipolar spectrum disorder and sleep-phase delay. Journal of Psychiatry & Neuroscience. 2010;35(2).
104 Coric V, Taskiran S, Pittenger C, Wasylink S, Mathalon DH, Valentine G, et al. Riluzole Augmentation in Treatment-Resistant Obsessive-Compulsive Disorder: An Open-Label Trial. Biological Psychiatry. 09. 2005;58(5):424-8. [pmid: 15993857].
105 Cornelius JR, Soloff PH, Perel JM, Ulrich RF. A preliminary trial of fluoxetine in refractory borderline patients. Journal of Clinical Psychopharmacology. 04. 1991;11(2):116-20. [pmid: 2056138].
106 Crippa JAS, Hallak JEC, Zuardi AW, Chagas MHN, Quevedo J, Nardi AE. Agomelatine in the treatment of social anxiety disorder. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 2010;34(7):1357-8. [pmid: 20637821].
107 Critchley HD, Lewis PA, Orth M, Josephs O, Deichmann R, Trimble MR, et al. Vagus nerve stimulation for treatment-resistant depression: behavioral and neural effects on encoding negative material. Psychosomatic Medicine. Jan. 2007;69(1):17-22. [pmid: 17244844].
108 Cukiert A, Burattini JA, Cukiert CM, Argentoni-Baldochi M, Baise-Zung C, Forster CR, et al. Centro-median stimulation yields additional seizure frequency and attention improvement in patients previously submitted to callosotomy. Seizure. 2009;18(8):588-92. [pmid: 19577937].
109 Curtin F, Berney P, Kaufmann C. Moclobemide discontinuation syndrome predominantly presenting with influenza-like symptoms. Journal of Psychopharmacology. 09. 2002;16(3):271-2. [pmid: 12236637].
110 Dannon PN, Grunhaus L. Effect of electroconvulsive therapy in repetitive transcranial magnetic stimulation non-responder MDD patients: A preliminary study. International Journal of Neuropsychopharmacology. Sep. 2001;4(3):265-8. [pmid: 11602032].
111 Davanloo H. Intensive short-term dynamic psychotherapy: Technique of partial and major unlocking of the unconscious with a highly resistant patient: I Partial unlocking of the unconscious. International Journal of Short-Term Psychotherapy. Sep-Dec. 1995;10(3):157-81.
112 Davenhill R, editor. Looking into later life: A psychoanalytic approach to depression and dementia in old age. London, England. Karnac Books. 2007.
113 Davis A, Zisselman M, Simmons T, McCall WV, McCafferty J, Rosenquist PB. Electroconvulsive therapy in the setting of implantable cardioverter-defibrillators. The Journal of ECT. 2009;25(3):198-201. [pmid: 19300291].
114 Davis MH, Casey DA. Utilizing cognitive therapy on the short-term psychiatric inpatient unit. General Hospital Psychiatry. May. 1990;12(3):170-6. [pmid: 2335303].
115 de la Fuente JR, Berlanga C, León-Andrade C. Mania induced by tricyclic-MAOI combination therapy in bipolar treatment-resistant disorder: Case reports. Journal of Clinical Psychiatry. 01. 1986;47(1):40-1. [pmid: 3941059].
116 de Macedo-Soares MB, Moreno RA, Rigonatti SP, Lafer B. Efficacy of Electroconvulsive Therapy in Treatment-Resistant Bipolar Disorder: A Case Series. The Journal of ECT. 03. 2005;21(1):31-4. [pmid: 15791175].
117 de Montigny C, Silverstone PH, Debonnel G, Blier P, Bakish D. Venlafaxine in treatment-resistant major depression: A Canadian multicenter, open-label trial. Journal of Clinical Psychopharmacology. 10. 1999;19(5):401-6. [pmid: 10505581].
118 Dejonge P, Honig A, Van Melle JP, Schene AH, Kuyper AMG, Tulner D, et al. Nonresponse to treatment for depression following myocardial infarction: Association with subsequent cardiac events. The American Journal of Psychiatry. 09. 2007;164(9):1371-8. [pmid: 17728422].
119 del Olmo MFn, Bello O, Cudeiro J. Transcranial magnetic stimulation over dorsolateral prefrontal cortex in Parkinson's disease. Clinical Neurophysiology. Jan. 2007;118(1):131-9. [pmid: 17097342].
120 Dell'Osso B, Dario A, Ciabatti M, Camuri G, Oldani L, Balossi I, et al. Vagus nerve stimulation in treatment-resistant bipolar depression. Clinical Neuropsychiatry: Journal of Treatment Evaluation. 2009;6(6):252-8.
121 Dell'Osso B, Mundo E, D'Urso N, Pozzoli S, Buoli M, Ciabatti MT, et al. Augmentative repetitive navigated transcranial magnetic stimulation (rTMS) in drug-resistant bipolar depression. Bipolar Disorders. Feb. 2009;11(1):76-81. [pmid: 19133969].
122 Devarajan S, Ali J, Dursun SM. Quetiapine plus SSRI in treatment-resistant depression: Possible mechanisms. Psychopharmacology. 04. 2006;185(3):402-3. [pmid: 16538471].
123 Devarajan S, Dursun SM. Olanzapine plus venlafaxine in treatment-resistant depression. Journal of Psychopharmacology. 07. 2005;19(4):434-5. [pmid: 15983004].
124 Di Lazzaro V, Dileone M, Profice P, Pilato F, Oliviero A, Mazzone P, et al. LTD-like plasticity induced by paired associative stimulation: Direct evidence in humans. Experimental Brain Research. Apr. 2009;194(4):661-4.
125 Dilbaz N, Sengü C, Okay T, Bayam Gk, Türkoglu A. The combined treatment of venlafaxine and ECT in treatment-resistant depressive patients. International Journal of Psychiatry in Clinical Practice. 03. 2005;9(1):55-9.
126 Dinan T, Siggins L, Scully P, O'Brien S, Ross P, Stanton C. Investigating the inflammatory phenotype of major depression: Focus on cytokines and polyunsaturated fatty acids. Journal of Psychiatric Research. 01. 2009;43(4):471-6. [pmid: 18640689].
127 Dolberg OT, Dannon PN, Schreiber S, Grunhaus L. Magnetic motor threshold and response to TMS in major depressive disorder. Acta Psychiatrica Scandinavica. Sep. 2002;106(3):220-3. [pmid: 12197860].
128 Dolberg OT, Schreiber S, Grunhaus L. Transcranial magnetic stimulation-induced switch into mania: A report of two cases. Biological Psychiatry. Mar. 2001;49(5):468-70. [pmid: 11274660].
129 Dudek D, Rybakowski JK, Siwek M, Pawłowski T, Lojko D, Roczeń R, et al. Risk factors of treatment resistance in major depression: Association with bipolarity. Journal of Affective Disorders. 2010;126(1-2):268-71. [pmid: 20381154].
130 Duhameau B, Ferré JC, Jannin P, Gauvrit JY, Vérin M, Millet B, et al. Chronic and treatment-resistant depression: A study using arterial spin labeling perfusion MRI at 3 Tesla. Psychiatry Research: Neuroimaging. 2010;182(2):111-6.
131 Dunn NJ, Yanasak E, Schillaci J, Simotas S, Rehm LP, Souchek J, et al. Personality Disorders in Veterans With Posttraumatic Stress Disorder and Depression. Journal of Traumatic Stress. Feb. 2004;17(1):75-82. [pmid: 15027797].
132 Ebert A, Jochum T, Ritter J, Boettger MK, Schulz S, Voss A, et al. Does parasympathetic modulation prior to ECT treatment influence therapeutic outcome?. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 2010;34(7):1174-80. [pmid: 20600469].
133 Egger C, Muehlbacher M, Grohmann R, Stuppaeck C. Clozapine intoxication in a patient with lamotrigine-induced rash. Pharmacopsychiatry. 2010;43(1):35-6. [pmid: 20013554].
134 Ehnvall A, Mitchell PB, Hadzi-Pavlovic D, Malhi GS, Parker G. Pain during depression and relationship to rejection sensitivity. Acta Psychiatrica Scandinavica. 2009;119(5):375-82. [pmid: 19076116].
135 Eisenberg J, Asnis G. Are antidepressant trials too short? A case report. Journal of Clinical Psychiatry. 01. 1986;47(1):38-9. [pmid: 3941057].
136 Ella R, Zwanzger P, Stampfer R, Preuss UW, Müller-Siecheneder F, Möller HJ, et al. Switch to mania after slow rTMS of the right prefrontal cortex. Journal of Clinical Psychiatry. Mar. 2002;63(3):249. [pmid: 11926727].
137 Elliott RE, Carlson C, Kalhorn SP, Moshel YA, Weiner HL, Devinsky O, et al. Refractory epilepsy in tuberous sclerosis: Vagus nerve stimulation with or without subsequent resective surgery. Epilepsy & Behavior. 2009;16(3):454-60. [pmid: 19767244].
138 Emsley RA, Buckley P, Jones AM, Greenwood MR. Differential effect of quetiapine on depressive symptoms in patients with partially responsive schizophrenia. Journal of Psychopharmacology. 06. 2003;17(2):210-5. [pmid: 12870569].
139 Emslie GJ, Mayes T, Porta G, Vitiello B, Clarke G, Wagner KD, et al. Treatment of resistant depression in adolescents (TORDIA): Week 24 outcomes. The American Journal of Psychiatry. 2010;167(7):782-91. [pmid: 20478877].
140 Englisch S, Esser A, Zink M. Bupropion for depression in schizophrenia: A case report. Pharmacopsychiatry. 2010;43(1):38-9. [pmid: 20178095].
141 Epstein BH. The use of humor in cognitive-behavioral therapy with outpatient depressed male adolescents. Dissertation Abstracts International: Section B: The Sciences and Engineering. Mar. 1997;57(9):5915.
142 Epstein CM, Figiel GS, McDonald WM, Amazon-Leece J, Figiel L. Rapid rate transcranial magnetic stimulation in young and middle-aged refractory depressed patients. Psychiatric Annals. Jan. 1998;28(1):36-9.
143 Ergene E, Behr PK, Shih JJ. Quality-of-life assessment in patients treated with vagus nerve stimulation. Epilepsy & Behavior. Jun. 2001;2(3):284-7. [pmid: 12609371].
144 Eschweiler GW, Plewnia C, Batra A, Bartels M. Does clinical response to repetitive prefrontal transcranial magnetic stimulation (rTMS) predict response to electroconvulsive therapy (ECT) in cases of major depression?. The Canadian Journal of Psychiatry. La Revue canadienne de psychiatrie. Nov. 2000;45(9):845-6.
145 Eschweiler GW, Wegerer C, Schlotter W, Spandl C, Stevens A, Bartels M, et al. Left prefrontal activation predicts therapeutic effects of repetitive transcranial magnetic stimulation (rTMS) in major depression. Psychiatry Research: Neuroimaging. Oct. 2000;99(3):161-72.
146 Evers S, Hangst K, Pecuch PW. The impact of repetitive transcranial magnetic stimulation on pituitary hormone levels and cortisol in healthy subjects. Journal of Affective Disorders. Sep. 2001;66(1):83-8. [pmid: 11532537].
147 Fagen TS, Wool CA. Conjoint therapy: Psychiatry and music therapy in the treatment of psychosomatic illness. Int J Arts Medicine. 1999;6(1):4-9.
148 Fahy TJ. Side effects of moclobemide in depressed patients refractory to other treatments. Irish Journal of Psychological Medicine. Feb. 1993;10(1):24-7.
149 Falconer DW, Cleland J, Fielding S, Reid IC. Using the Cambridge Neuropsychological Test Automated Battery (CANTAB) to assess the cognitive impact of electroconvulsive therapy on visual and visuospatial memory. Psychological Medicine: A Journal of Research in Psychiatry and the Allied Sciences. 2010;40(6):1017-25.
150 Faravelli C, Albanesi G, Sessarego A. Viqualine in resistant depression: A double-blind, placebo-controlled trial. Neuropsychobiology. 1988;20(2):78-81. [pmid: 3075725].
151 Fasano A, Romito LM, Daniele A, Piano C, Zinno M, Bentivoglio AR, et al. Motor and cognitive outcome in patients with Parkinson's disease 8 years after subthalamic implants. Brain: A Journal of Neurology. 2010;133(9):2664-76. [pmid: 20802207].
152 Fava M, Alpert J, Nierenberg A, Lagomasino I, Sonawalla S, Tedlow J, et al. Double-blind study of high-dose fluoxetine versus lithium or desipramine augmentation of fluoxetine in partial responders and nonresponders to fluoxetine. Journal of Clinical Psychopharmacology. 08. 2002;22(4):379-87. [pmid: 12172337].
153 Fawcett J. A 55-year-old Man With Long-term Refractory Depression. Psychiatric Annals. 06. 2006;36(6):384-6.
154 Fàzzari G, Benzoni O, Sangaletti A, Bonera F, Nassini S, Mazzarini L, et al. Improvement of cognition in a patient with Cotard's delusions and frontotemporal atrophy receiving electroconvulsive therapy (ECT) for depression. International Psychogeriatrics. 2009;21(3):600-3. [pmid: 19368757].
155 Fe-Bornstein M, Watt SD, Gitlin MC. Improvement in the level of psychosocial functioning in chronic pain patients with the use of risperidone. Pain Medicine. 06. 2002;3(2):128-31. [pmid: 15102159].
156 Fecteau GW. Treatment of posttraumatic stress reactions to traffic accidents. Dissertation Abstracts International: Section B: The Sciences and Engineering. Jul. 2000;61(1):527.
157 Feder R. Lithium augmentation of clomipramine. Journal of Clinical Psychiatry. 11. 1988;49(11):458. [pmid: 3141389].
158 Feijo de Mello M. Mirtazapine effectiveness in a patient with refractory psychotic depression. International Journal of Psychiatry in Clinical Practice. 06. 1999;3(2):141-2.
159 Ferrucci R, Bortolomasi M, Vergari M, Tadini L, Salvoro B, Giacopuzzi M, et al. Transcranial direct current stimulation in severe, drug-resistant major depression. Journal of Affective Disorders. 11. 2009;118(1):215-9. [pmid: 19286265].
160 Figiel GS, Epstein C, McDonald WM, Amazon-Leece J, Figiel L, Saldivia A, et al. The use of rapid-rate transcranial magnetic stimulation (rTMS) in refractory depressed patients. Journal of Neuropsychiatry & Clinical Neurosciences. Win. 1998;10(1):20-5. [pmid: 9547462].
161 Fischer P, Tauscher J, Küfferle B, Kasper S. Weak antidepressant response after buspirone augmentation of serotonin reuptake inhibitors in refractory severe depression. International Clinical Psychopharmacology. 03. 1998;13(2):83-6. [pmid: 9669189].
162 Fitzgerald PB, Benitez J, de Castella AR, Brown TL, Daskalakis ZJ, Kulkarni J. Naturalistic study of the use of transcranial magnetic stimulation in the treatment of depressive relapse. Australian and New Zealand Journal of Psychiatry. Sep. 2006;40(9):764-8. [pmid: 16911751].
163 Fitzgerald PB, Hoy K, Daskalakis ZJ, Kulkarni J. A randomized trial of the anti-depressant effects of low- and high-frequency transcranial magnetic stimulation in treatment-resistant depression. Depression and Anxiety. Mar. 2009;26(3):229-34. [pmid: 19105212].
164 Fontaine D, Lanteri-Minet M, Ouchchane L, Lazorthes Y, Mertens P, Blond S, et al. Anatomical location of effective deep brain stimulation electrodes in chronic cluster headache. Brain: A Journal of Neurology. 2010;133(4):1214-23. [pmid: 20237130].
165 Fontaine D, Lazorthes Y, Mertens P, Blond S, Géraud G, Fabre N, et al. Safety and efficacy of deep brain stimulation in refractory cluster headache: A randomized placebo-controlled double-blind trial followed by a 1-year open extension. The Journal of Headache and Pain. 2010;11(1):23-31. [pmid: 19936616].
166 Ford HE, Jenike MA. Erythema multiforme associated with trazodone therapy: Case report. Journal of Clinical Psychiatry. 07. 1985;46(7):294-5. [pmid: 4008456].
167 Fostick L, Silberman A, Beckman M, Spivak B, Amital D. The economic impact of depression: Resistance or severity?. European Neuropsychopharmacology. 2010;20(10):671-5. [pmid: 20624674].
168 Frank E, Grochocinski VJ, Spanier CA, Buysse DJ, Cherry CR, Houck PR, et al. Interpersonal psychotherapy and antidepressant medication: Evaluation of a sequential treatment strategy in women with recurrent major depression. Journal of Clinical Psychiatry. Jan. 2000;61(1):51-7. [pmid: 10695647].
169 Franzini A, Messina G, Gambini O, Muffatti R, Scarone S, Cordella R, et al. Deep-brain stimulation of the nucleus accumbens in obsessive compulsive disorder: Clinical, surgical and electrophysiological considerations in two consecutive patients. Neurological Sciences. 2010;31(3):353-9. [pmid: 20127500].
170 Fregni F, Merabet L, Pascual-Leone A, Marcolin MA. Modulation in motor threshold after a severe episode of gastrointestinal distress. Journal of ECT. 2004;20(1):50-1. [pmid: 15087999].
171 Fujita K, Koga Y. Clinical application of single-pulse transcranial magnetic stimulation for the treatment of depression. Psychiatry and Clinical Neurosciences. Aug. 2005;59(4):425-32. [pmid: 16048448].
172 Furubayashi T, Terao Y, Arai N, Okabe S, Mochizuki H, Hanajima R, et al. Short and long duration transcranial direct current stimulation (tDCS) over the human hand motor area. Experimental Brain Research. Feb. 2008;185(2):279-86.
173 Fux M, Benjamin J, Nemets B. A placebo-controlled cross-over trial of adjunctive EPA in OCD. Journal of Psychiatric Research. 05. 2004;38(3):323-5. [pmid: 15003438].
174 Garber A, Gregory RJ. Benztropine in the treatment of venlafaxine-induced sweating. Journal of Clinical Psychiatry. Apr. 1997;58(4):176-7. [pmid: 9164433].
175 Garcia RF, Dias AG, de Freitas AR, Fontenelle LF. Short-lived response of cervical dystonia to electroconvulsive therapy. The Journal of ECT. 2009;25(2):135-6. [pmid: 19145211].
176 Garcia-Toro M, Pascual-Leone A, Romera M, Gonzalez A, Micó J, Ibarra O, et al. Prefrontal repetitive transcranial magnetic stimulation as add on treatment for depression. Journal of Neurology, Neurosurgery & Psychiatry. Oct. 2001;71(4):546-8.
177 Garety PA, Kuipers L, Fowler D, Chamberlain F, et al. Cognitive behavioural therapy for drug-resistant psychosis. British Journal of Medical Psychology. Sep. 1994;67(3):259-71. [pmid: 7803318].
178 Gazdag G, Molnár E, Ungvari GS, Iványi Z. Knowledge of and attitude toward electroconvulsive therapy: A survey of Hungarian anesthesiology residents. The Journal of ECT. 2009;25(2):113-6. [pmid: 18978603].
179 Geller V, Grisaru N, Abarbanel JM, Lemberg T, Belmaker RH. Slow magnetic stimulation of prefrontal cortex in depression and schizophrenia. Progress in Neuro-Psychopharmacology & Biological Psychiatry. Jan. 1997;21(1):105-10. [pmid: 9075260].
180 George MS, Nahas Z, Molloy M, Speer AM, Oliver NC, Li XB, et al. A controlled trial of daily left prefrontal cortex TMS for treating depression. Biological Psychiatry. Nov. 2000;48(10):962-70. [pmid: 11082469].
181 George MS, Sackeim HA, Marangell LB, Husain MM, Nahas Z, Lisanby SH, et al. Vagus nerve stimulation: A potential therapy for resistant depression?. Psychiatric Clinics of North America. Dec. 2000;23(4):757-83. [pmid: 11147246].
182 George MS, Speer AM, Molloy M, Nahas Z, Teneback CC, Risch SC, et al. Low frequency daily left prefrontal rTMS improves mood in bipolar depression: A placebo-controlled case report. Human Psychopharmacology: Clinical and Experimental. Jun. 1998;13(4):271-5.
183 George MS, Ward HE Jr, Ninan PT, Pollack M, Nahas Z, Anderson B, et al. A pilot study of vagus nerve stimulation (VNS) for treatment-resistant anxiety disorders. Brain Stimulation. Apr. 2008;1(2):112-21. [pmid: 20633378].
184 George MS, Wassermann EM, Williams WA, Callahan A, et al. Daily repetitive transcranial magnetic stimulation (rTMS) improves mood in depression. Neuroreport: An International Journal for the Rapid Communication of Research in Neuroscience. Oct. 1995;6(14):1853-6.
185 George T, Theodoros MT, Chiu E, Krapivensky N, Hokin A, Tiller JWG. An open study of sertraline in patients with major depression who failed to respond to moclobemide. Australian and New Zealand Journal of Psychiatry. 12. 1999;33(6):889-95. [pmid: 10619217].
186 Germain A, Shear MK, Hall M, Buysse DJ. Effects of a brief behavioral treatment for PTSD-related sleep disturbances: A pilot study. Behaviour Research and Therapy. Mar. 2007;45(3):627-32. [pmid: 16777060].
187 Ginsberg DL. Adjunctive Ropinirole for Treatment-Resistant Depression. Primary Psychiatry. 08. 2005;12(8):26-7.
188 Ginsberg DL. Aripiprazole Augmentation for Treatment-Resistant Depression. Primary Psychiatry. 06. 2005;12(6):26-7.
189 Ginsberg DL. Transdermal (but not oral) selegiline effective for treatment-resistant depression. Primary Psychiatry. 2007;14(7).
190 Glezer A, Murray E, Price B, Cunningham M. Effective use of electroconvulsive therapy after craniofacial reconstructive surgery. The Journal of ECT. 2009;25(3):208-9. [pmid: 19145209].
191 Goldberg JF, Burdick KE, Endick CJ. Preliminary Randomized, Double-Blind, Placebo-Controlled Trial of Pramipexole Added to Mood Stabilizers for Treatment-Resistant Bipolar Depression. The American Journal of Psychiatry. 03. 2004;161(3):564-6. [pmid: 14992985].
192 Goldstein BI, Shamseddeen W, Spirito A, Emslie G, Clarke G, Wagner KD, et al. Substance use and the treatment of resistant depression in adolescents. Journal of the American Academy of Child & Adolescent Psychiatry. 2009;48(12):1182-92. [pmid: 19858762].
193 Gonul AS, Akdeniz F, Donat O, Vahip S. Selective serotonin reuptake inhibitors combined with venlafaxine in depressed patients who had partial response to venlafaxine: Four cases. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 08. 2003;27(5):889-91. [pmid: 12921926].
194 Goodman WK, Foote KD, Greenberg BD, Ricciuti N, Bauer R, Ward H, et al. Deep brain stimulation for intractable obsessive compulsive disorder: Pilot study using a blinded, staggered-onset design. Biological Psychiatry. 2010;67(6):535-42. [pmid: 20116047].
195 Gormly N, Cullen C, Watters L, Philpot M, Lawlor BA. Does psychosis predict response to ECT in depressed elderly patients?. Irish Journal of Psychological Medicine. Mar. 1999;16(1):13-5.
196 Govender S, Drummond LM, Menzies RG. Danger ideation reduction therapy for the treatment of severe, chronic and resistant obsessive-compulsive disorder. Behavioural and Cognitive Psychotherapy. Oct. 2006;34(4):477-80.
197 Graf T, Engeler J, Achermann P, Mosimann UP, Noss R, Fisch HU, et al. High frequency repetitive transcranial magnetic stimulation (rTMS) of the left dorsolateral cortex: EEG topography during waking and subsequent sleep. Psychiatry Research: Neuroimaging. Jul. 2001;107(1):1-9.
198 Graff-Radford J, Foote KD, Mikos AE, Bowers D, Fernandez HH, Rosado CA, et al. Mood and motor effects of thalamic deep brain stimulation surgery for essential tremor. European Journal of Neurology. 2010;17(8):1040-6. [pmid: 20113336].
199 Greenberg BD, Gabriels LA, Malone DA Jr, Rezai AR, Friehs GM, Okun MS, et al. Deep brain stimulation of the ventral internal capsule/ventral striatum for obsessive-compulsive disorder: Worldwide experience. Molecular Psychiatry. 2010;15(1):64-79. [pmid: 18490925].
200 Grimm S, Beck J, Schuepbach D, Hell D, Boesiger P, Bermpohl F, et al. Imbalance between left and right dorsolateral prefrontal cortex in major depression is linked to negative emotional judgment: An fMRI study in severe major depressive disorder. Biological Psychiatry. Feb. 2008;63(4):369-76. [pmid: 17888408].
201 Grisaru N, Bruno R, Pridmore S. Effect on the emotions of healthy individuals of slow repetitive transcranial magnetic stimulation applied to the prefrontal cortex. Journal of ECT. Sep. 2001;17(3):184-9. [pmid: 11528309].
202 Grunhaus L, Dolberg OT, Polak D, Dannon PN. Monitoring the response to rTMS in depression with visual analog scales. Human Psychopharmacology: Clinical and Experimental. Oct. 2002;17(7):349-52. [pmid: 12415554].
203 Guinjoan SM, Mayberg HS, Costanzo EY, Fahrer RD, Tenca E, Antico J, et al. Asymmetrical contribution of brain structures to treatment-resistant depression as illustrated by effects of right subgenual cingulum stimulation. The Journal of Neuropsychiatry and Clinical Neurosciences. 2010;22(3):265-77. [pmid: 20686133].
204 Habel U, Wild B, Topka H, Kircher T, Salloum JB, Schenider F. Transcranial magnetic stimulation: No effect on mood with single pulse during learned helplessness. Progress in Neuro-Psychopharmacology & Biological Psychiatry. Apr. 2001;25(3):497-506. [pmid: 11370993].
205 Hamner MB, Frueh BC. Response to venlafaxine in a previously antidepressant treatment-resistant combat veteran with post-traumatic stress disorder. International Clinical Psychopharmacology. 09. 1998;13(5):233-4. [pmid: 9817630].
206 Harden CL, Pulver MC, Ravdin LD, Nikolov B, Halper JP, Labar DR. A pilot study of mood in epilepsy patients treated with vagus nerve stimulation. Epilepsy & Behavior. Apr. 2000;1(2):93-9. [pmid: 12609137].
207 Hausmann A, Mangweth B, Walpoth M, Hoertnagel C, Kramer-Reinstadler K, Rupp CI, et al. Repetitive transcranial magnetic stimulation (rTMS) in the double-blind treatment of a depressed patient suffering from bulimia nervosa: A case report. International Journal of Neuropsychopharmacology. Sep. 2004;7(3):371-3. [pmid: 15154975].
208 Hausmann A, Pascual-Leone A, Kemmler G, Rupp CI, Lechner-Schoner T, Kramer-Reinstadler K, et al. No deterioration of cognitive performance in an aggressive unilateral and bilateral antidepressant rTMS add-on trial. Journal of Clinical Psychiatry. Jun. 2004;65(6):772-82. [pmid: 15291654].
209 Hawley C, Sivakumaran T, Huber TJ, Ige AK. Combination therapy with nefazodone and lithium: Safety and tolerability in fourteen patients. International Journal of Psychiatry in Clinical Practice. 12. 1998;2(4):251-4.
210 He W, Chai H, Zheng L, Yu W, Chen W, Li J, et al. Mismatch negativity in treatment-resistant depression and borderline personality disorder. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 2010;34(2):366-71. [pmid: 20074609].
211 Hellerstein DJ, Batchelder S, Hyler S, Arnaout B, Corpuz V, Coram L, et al. Aripiprazole as an adjunctive treatment for refractory unipolar depression. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 04. 2008;32(3):744-50. [pmid: 18164528].
212 Hennings JM, Owashi T, Binder EB, Horstmann S, Menke A, Kloiber S, et al. Clinical characteristics and treatment outcome in a representative sample of depressed inpatients--Findings from the Munich Antidepressant Response Signature (MARS) project. Journal of Psychiatric Research. 01. 2009;43(3):215-29. [pmid: 18586274].
213 Herwig U, Bräuer K, Connemann B, Spitzer M, Schönfeldt-Lecuona C. Intracortical excitability is modulated by a norepinephrine-reuptake inhibitor as measured with paired-pulse transcranial magnetic stimulation. Psychopharmacology. Nov. 2002;164(2):228-32. [pmid: 12404087].
214 Herwig U, Lampe Y, Juengling FD, Wunderlich A, Walter H, Spitzer M, et al. Add-on rTMS for treatment of depression: a pilot study using stereotaxic coil-navigation according to PET data. Journal of Psychiatric Research. Jul-Aug. 2003;37(4):267-75. [pmid: 12765849].
215 Higuchi H, Kamata M, Sugawara Y, Yoshida K. Remarkable Effect of Selegiline (L-Deprenyl), a Selective Monoamine Oxidase Type-B Inhibitor, in a Patient With Severe Refractory Depression: A Case Report. Clinical Neuropharmacology. 07. 2005;28(4):191-2. [pmid: 16062100].
216 Hirschmann S, Dannon PN, Iancu I, Dolberg OT, Zohar J, Grunhaus L. Pindolol augmentation in patients with treatment-resistant panic disorder: A double-blind, placebo controlled trial. Journal of Clinical Psychopharmacology. 10. 2000;20(5):556-9. [pmid: 11001241].
217 Höflich G, Kasper S, Hufnagel A, Ruhrmann S, Möller HJ. Application of transcranial magnetic stimulation in treatment of drug-resistant major depression: A report of two cases. Human Psychopharmacology: Clinical and Experimental. Sep-Oct. 1993;8(5):361-5.
218 Holroyd S, Durgee J. Venlafaxine in treatment refractory geriatric depression. Clinical Gerontologist: The Journal of Aging and Mental Health. 1998;18(3):39-50.
219 Holtzheimer P, Fawaz W, Wilson C, Avery D. Repetitive transcranial magnetic stimulation may induce language switching in bilingual patients. Brain and Language. Sep. 2005;94(3):274-7. [pmid: 16098377].
220 Hoppe C, Helmstaedter C, Scherrmann J, Elger CE. Self-reported mood changes following 6 months of vagus nerve stimulation in epilepsy patients. Epilepsy & Behavior. Aug. 2001;2(4):335-42. [pmid: 12609210].
221 Höppner J, Schulz M, Irmisch G, Mau R, Schläfke D, Richter J. Antidepressant efficacy of two different rTMS procedures: High frequency over left versus low frequency over right prefrontal cortex compared with sham stimulation. European Archives of Psychiatry and Clinical Neuroscience. 2003;253(2):103-9. [pmid: 12799750].
222 Hoy KE, Fitzgerald PB. Introducing magnetic seizure therapy: A novel therapy for treatment resistant depression. Australian and New Zealand Journal of Psychiatry. 2010;44(7):591-8. [pmid: 20560846].
223 Hrdlicka M. Combination of clozapine and maprotiline in refractory psychotic depression. European Psychiatry. 12. 2002;17(8):484. [pmid: 12504267].
224 Hsueh KL, Lin PY. Treatment-resistant depression prior to the diagnosis of cryptococcal meningitis: A case report. General Hospital Psychiatry. 2010;32(5):e9-e10. [pmid: 20851285].
225 Hu Y, Yu X, Yang F, Si T, Wang W, Tan Y, et al. The level of serum brain-derived neurotrophic factor is associated with the therapeutic efficacy of modified electroconvulsive therapy in Chinese patients with depression. The Journal of ECT. 2010;26(2):121-5. [pmid: 19935088].
226 Huang YZ, Rothwell JC, Edwards MJ, Chen RS. Effect of physiological activity on an NMDA-dependent form of cortical plasticity in human. Cerebral Cortex. Mar. 2008;18(3):563-70. [pmid: 17573373].
227 Huber R, Määttä S, Esser SK, Sarasso S, Ferrarelli F, Watson A, et al. Measures of cortical plasticity after transcranial paired associative stimulation predict changes in electroencephalogram slow-wave activity during subsequent sleep. Journal of Neuroscience. Jul. 2008;28(31):7911-8. [pmid: 18667623].
228 Husain MM, Stegman D, Trevino K. Pregnancy and delivery while receiving vagus nerve stimulation for the treatment of major depression: A case report. Annals of General Psychiatry. Sept. 2005;4. ArtID 16.
229 Hustig H, Onilov R. ECT rekindles pharmacological response in schizophrenia. European Psychiatry. 2009;24(8):521-5. [pmid: 19556109].
230 Iosifescu DV, Clementi-Craven N, Fraguas R, Papakostas GI, Petersen T, Alpert JE, et al. Cardiovascular Risk Factors May Moderate Pharmacological Treatment Effects in Major Depressive Disorder. Psychosomatic Medicine. 09. 2005;67(5):703-6. [pmid: 16204427].
231 Iosifescu DV, Nierenberg AA, Mischoulon D, Perlis RH, Papakostas GI, Ryan JL, et al. An Open Study of Triiodothyronine Augmentation of Selective Serotonin Reuptake Inhibitors in Treatment-Resistant Major Depressive Disorder. Journal of Clinical Psychiatry. 08. 2005;66(8):1038-42. [pmid: 16086620].
232 Isenberg K, Downs D, Pierce K, Svarakic D, Garcia K, Jarvis M, et al. Low Frequency rTMS Stimulation of the Right Frontal Cortex Is as Effective as High Frequency rTMS Stimulation of the Left Frontal Cortex for Antidepressant-Free, Treatment-Resistant Depressed Patients. Annals of Clinical Psychiatry. Jul-Sep. 2005;17(3):153-9. [pmid: 16433057].
233 Israël M, Steiger H, Kolivakis T, McGregor L, Sadikot AF. Deep brain stimulation in the subgenual cingulate cortex for an intractable eating disorder. Biological Psychiatry. 2010;67(9):e53-e4. [pmid: 20044072].
234 Ivanova JI, Birnbaum HG, Kidolezi Y, Subramanian G, Khan SA, Stensland MD. Direct and indirect costs of employees with treatment-resistant and non-treatment-resistant major depressive disorder. Current Medical Research and Opinion. 2010;26(10):2475-84. [pmid: 20825269].
235 Iwata K, Masuda M, Soejima K, Ohashi M. Combination of electroconvulsive therapy with skin graft surgery for a schizophrenic patient with burns. The Journal of ECT. 2009;25(3):210-2. [pmid: 19190512].
236 Jaafari N, Brzozowski M, Rotge JY, Sharov I, Bates H, Paillot C, et al. ECT as a ‘therapeutic test’ to differentiate pharmaco-resistant depression from dementia in the elderly: A pilot study. Primary Care & Community Psychiatry. 2008;13(4):155-61.
237 Janssen J, Pol HEH, Schnack HG, Kok RM, Lampe IK, de Leeuw FE, et al. Cerebral volume measurements and subcortical white matter lesions and short-term treatment response in late life depression. International Journal of Geriatric Psychiatry. 05. 2007;22(5):468-74. [pmid: 17357181].
238 Jeyapaul P, Vieweg R. A case study evaluating the use of clozapine in depression with psychotic features. Annals of General Psychiatry. 2006;11:5.
239 Joffe H, Groninger H, Soares C, Nonacs R, Cohen LS. An open trial of mirtazapine in menopausal women with depression unresponsive to estrogen replacement therapy. Journal of Women's Health & Gender-Based Medicine. 12. 2001;10(10):999-1004.
240 Johnson BA, Cowen PJ. Calcium channel blockade and resistant bipolar depression. Irish Journal of Psychological Medicine. Mar. 1991;8(1):50-1.
241 Juruena MF, Pariante CM, Papadopoulos As, Poon L, Lightman S, Cleare AJ. Prednisolone suppression test in depression: Prospective study of the role of HPA axis dysfunction in treatment resistance. British Journal of Psychiatry. 04. 2009;194(4):342-9. [pmid: 19336786].
242 Kalayam B, Alexopoulos GS. Prefrontal dysfunction and treatment response in geriatric depression. Archives of General Psychiatry. 08. 1999;56(8):713-8. [pmid: 10435605].
243 Kamath V, Kamath S, Ramkisson R. Maintenance ECT over nine years in schizoaffective disorder. German Journal of Psychiatry. 2010;13(2):100-3.
244 Kanai A, Okamoto H. Paroxetine improves pain and depression in patients with refractory chronic pain. The Pain Clinic. 2007;19(5):235-9.
245 Kaplan EM. Efficacy of venlafaxine in patients with major depressive disorder who have unsustained or no response to selective serotonin reuptake inhibitors: An open-label, uncontrolled study. Clinical Therapeutics: The International Peer-Reviewed Journal of Drug Therapy. 07. 2002;24(7):1194-200.
246 Kapstan A, Yaroslavsky Y, Applebaum J, Belmaker RH, Grisaru N. Right prefrontal TMS versus sham treatment of mania: A controlled study. Bipolar Disorders. Feb. 2003;5(1):36-9.
247 Karp JF, Reynolds CF III. Pharmacotherapy of Depression in the Elderly: Achieving and Maintaining Optimal Outcomes. Primary Psychiatry. May. 2004;11(5):37-46.
248 Katona CLE, Abou-Saleh MT, Harrison DA, Nairac BA. Placebo-controlled trial of lithium augmentation of fluoxetine and lofepramine. British Journal of Psychiatry. 01. 1995;166:80-6. [pmid: 7894881].
249 Katsikitis M, Pridmore S, Marzullo M. The facial expression measurement system in the assessment of the efficacy of transcranial magnetic stimulation in the treatment of depression. European Review of Applied Psychology. 1999;49(2):123-9.
250 Kaya B, Güzelipek M, Özcan ME. Severe extrapyramidal symptoms due to sulpiride and fluoxetine combination in a case of OCD. Klinik Psikofarmakoloji Bülteni. 2001;11(2):121-3.
251 Kayser S, Bewernick B, Axmacher N, Schlaepfer TE. Magnetic seizure therapy of treatment-resistant depression in a patient with bipolar disorder. The Journal of ECT. 06. 2009;25(2):137-40. [pmid: 19057399].
252 Keddy P, Erdberg P. Changes in the Rorschach and MMPI-2 after electroconvulsive therapy (ECT): A collaborative assessment case study. Journal of Personality Assessment. 2010;92(4):279-95. [pmid: 20552503].
253 Keitner GI, Garlow SJ, Ryan CE, Ninan PT, Solomon DA, Nemeroff CB, et al. A randomized, placebo-controlled trial of risperidone augmentation for patients with difficult-to-treat unipolar, non-psychotic major depression, Journal of Psychiatric Research. Netherlands. Elsevier Science. 2009:205-14.
254 Kellner CH, Tobias KG, Jakubowski LM, Ali Z, Istafanous RM. Electroconvulsive therapy for an urgent social indication. The Journal of ECT. 2009;25(4):274-5. [pmid: 19455061].
255 Kellner M. Aripiprazole in a therapy-resistant patient with borderline personality and post-traumatic stress disorder. Pharmacopsychiatry. Jan. 2007;40(1):41. [pmid: 17327963].
256 Kelly T, Lieberman DZ. The use of triiodothyronine as an augmentation agent in treatment-resistant bipolar II and bipolar disorder NOS. Journal of Affective Disorders. 2009;116(3):202-26.
257 Kemp DE, Gilmer WS, Fleck J, Straus JL, Dago PL, Karaffa M. Aripiprazole augmentation in treatment-resistant bipolar depression: Early response and development of akathisia. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 03. 2007;31(2):574-7. [pmid: 17234318].
258 Kemp DE, Ismail-Beigi F, Calabrese JR. Antidepressant response associated with pioglitazone: Support for an overlapping pathophysiology between major depression and metabolic syndrome. The American Journal of Psychiatry. 2009;166(5).
259 Kennard BD, Clarke GN, Weersing VR, Asarnow JR, Shamseddeen W, Porta G, et al. Effective components of TORDIA cognitive–behavioral therapy for adolescent depression: Preliminary findings. Journal of Consulting and Clinical Psychology. 2009;77(6):1033-41. [pmid: 19968380].
260 Kennedy SH, Segal ZV, Cohen NL, Levitan RD, Gemar M, Bagby RM. Lithium carbonate versus cognitive therapy as sequential combination treatment strategies in partial responders to antidepressant medication: An exploratory trial. Journal of Clinical Psychiatry. Apr. 2003;64(4):439-44. [pmid: 12716247].
261 Kennedy T, Jones R, Darnley S, Seed P, Wessely S, Chalder T. Cognitive behaviour therapy in addition to antispasmodic treatment for irritable bowel syndrome in primary care: Randomised controlled trial. British Medical Journal. Aug. 2005;331(7514):435. [pmid: 16093252].
262 Kenny MA, Williams JMG. Treatment-resistant depressed patients show a good response to Mindfulness-based Cognitive Therapy. Behaviour Research and Therapy. Mar. 2007;45(3):617-25. [pmid: 16797486].
263 Kent LK, Weston CA, Heyer EJ, Sherman W, Prudic J. Successful retrial of ECT two months after ECT-induced takotsubo cardiomyopathy. The American Journal of Psychiatry. 2009;166(8):857-62. [pmid: 19651751].
264 Khan AY, Golewale M. Significant weight loss in a young adult man. Psychiatric Annals. Mar. 4. 2007;37(3):152-7.
265 Kibler JL, Lyons JA. Brief cognition-focused group therapy for depressive symptoms in chronic posttraumatic stress disorder: A pilot study. J Psychological Trauma. 2008;7(2):122-38.
266 Kiejna A, Pawłowski T, Dudek D, Łojko D, Siwek M, Roczeń R, et al. The utility of Mood Disorder Questionnaire for the detection of bipolar diathesis in treatment-resistant depression. Journal of Affective Disorders. 2010;124(3):270-4. [pmid: 20060173].
267 Kinrys G, Wygant LE, Pardo TB, Melo M. Levetiracetam for Treatment-Refractory Posttraumatic Stress Disorder. Journal of Clinical Psychiatry. 02. 2006;67(2):211-4. [pmid: 16566615].
268 Kishida I, Aklillu E, Kawanishi C, Bertilsson L, Agren H. Monoamine metabolites level in CSF is related to the 5-HTT gene polymorphism in treatment-resistant depression. Neuropsychopharmacology. 10. 2007;32(10):2143-51. [pmid: 17299512].
269 Klein P, Oertel J. Depression associated with pontine vascular malformation. Biological Psychiatry. 09. 1997;42(6):519-21. [pmid: 9285088].
270 Kocabas NA, Faghel C, Barreto M, Kasper S, Linotte S, Mendlewicz J, et al. The impact of catechol-O-methyltransferase SNPs and haplotypes on treatment response phenotypes in major depressive disorder: A case-control association study. International Clinical Psychopharmacology. 2010;25(4):218-27. [pmid: 20531207].
271 Kolbinger HM, Höflich G, Hufnagel A, Möller HJ, Kasper S. Transcranial magnetic stimulation (TMS) in the treatment of major depression: A pilot study. Human Psychopharmacology: Clinical and Experimental. Jul-Aug. 1995;10(4):305-10.
272 Kosel M, Frick C, Lisanby SH, Fisch HU, Schlaepfer TE. Magnetic seizure therapy improves mood in refractory major depression. Neuropsychopharmacology. Nov. 2003;28(11):2045-8. [pmid: 12942146].
273 Kosel M, Sturm V, Frick C, Lenartz D, Zeidler G, Brodesser D, et al. Mood improvement after deep brain stimulation of the internal globus pallidus for tardive dyskinesia in a patient suffering from major depression. Journal of Psychiatric Research. 11. 2007;41(9):801-3. [pmid: 16962613].
274 Koutroumanidis M, Binnie CD, Hennessy MJ, Alarcon G, Elwes RDC, Toone BK, et al. VNS in patients with previous unsuccessful resective epilepsy surgery: Antiepileptic and psychotropic effects. Acta Neurologica Scandinavica. Feb. 2003;107(2):117-21. [pmid: 12580861].
275 Kozel FA, George MS, Simpson KN. Decision Analysis of Cost-Effectiveness of Repetitive Transcranial Magnetic Stimulation Versus Electroconvulsive Therapy for Treatment of Nonpsychotic Severe Depression. CNS Spectrums. Jun. 2004;9(6):476-82. [pmid: 15162090].
276 Kozel FA, Nahas Z, deBrux C, Molloy M, Lorberbaum JP, Bohning D, et al. How coil-cortex distance relates to age, motor threshold, and antidepressant response to repetitive transcranial magnetic stimulation. Journal of Neuropsychiatry & Clinical Neurosciences. Sum. 2000;12(3):376-84. [pmid: 10956572].
277 Krahn LE, Gleber E, Rummans TA, Pileggi TS, Lucas DL, Li H. The effects of electroconvulsive therapy on melatonin. The Journal of ECT. 12. 2000;16(4):391-8. [pmid: 11314877].
278 Kraus RP. Pindolol augmentation of tranylcypromine in psychotic depression. Journal of Clinical Psychopharmacology. 06. 1997;17(3):225-6. [pmid: 9169970].
279 Krochmalik A, Jones MK, Menzies RG. Danger Ideation Reduction Therapy (DIRT) for treatment-resistant compulsive washing. Behaviour Research and Therapy. Aug. 2001;39(8):897-912. [pmid: 11480831].
280 Krymchantowski AV, Jevoux C, Moreira PF. An open pilot study assessing the benefits of quetiapine for the prevention of migraine refractory to the combination of atenolol, nortriptyline, and flunarizine. Pain Medicine. 2010;11(1):48-52. [pmid: 20002594].
281 Kuipers E, Garety P, Fowler D, Dunn G, Bebbington P, Freeman D, et al. London-East Anglia randomised controlled trial of cognitive-behavioural therapy for psychosis I: Effects of the treatment phase. British Journal of Psychiatry. Oct. 1997;171:319-27. [pmid: 9373419].
282 Kumagai R, Ichimiya Y. Efficacy of blonanserin in combination therapy for treatment-resistant depression. Psychiatry and Clinical Neurosciences. 2009;63(4):593-4. [pmid: 19659567].
283 Lam RW, Bartley S, Yatham LN, Tam EM, Zis AP. Clinical predictors of short-term outcome in electroconvulsive therapy. The Canadian Journal of Psychiatry. La Revue canadienne de psychiatrie. 03. 1999;44(2):158-63.
284 Landén M, Björling Gr, Agren H, Fahlén T. A randomized, double-blind, placebo-controlled trial of busiprone in combination with an SSRI in patients with treatment-refractory depression. Journal of Clinical Psychiatry. 12. 1998;59(12):664-8. [pmid: 9921700].
285 Landreville P, Bissonnette L. Effects of cognitive bibliotherapy for depressed older adults with a disability. Clinical Gerontologist. 1997;17(4):35-55.
286 Langius-Eklöf A, Samuelsson M. Sense of coherence and psychiatric morbidity in terms of anxiety and depression in patients with major depression before and after electric convulsive treatment. Scandinavian Journal of Caring Sciences. 2009;23(2):375-9. [pmid: 19645810].
287 Lee J. Potential risks for the off-label use of SSRIs in premature ejaculation. Journal of Sexual Medicine. 2010;7(8):2622-4. [pmid: 21711474].
288 Lefaucheur JP, Drouot X, Cunin P, Bruckert R, Lepetit H, Créange A, et al. Motor cortex stimulation for the treatment of refractory peripheral neuropathic pain. Brain: A Journal of Neurology. 2009;132(6):1463-71. [pmid: 19336459].
289 Lerer B, Isserles M. From Meduna to ultrabrief: New directions for the oldest brain stimulation therapy. Brain Stimulation. Apr. 2008;1(2):84-5. [pmid: 20633372].
290 Levit-Binnun N, Litvak V, Pratt H, Moses E, Zaroor M, Peled A. Differences in TMS-evoked responses between schizophrenia patients and healthy controls can be observed without a dedicated EEG system. Clinical Neurophysiology. 2010;121(3):332-9. [pmid: 20006543].
291 Lévy-Rueff M, Gourevitch R, Lôo H, Olié JP, Amado I. Maintenance electroconvulsive therapy: An alternative treatment for refractory schizophrenia and schizoaffective disorders. Psychiatry Research. 2010;175(3):280-3. [pmid: 20034675].
292 Leyman L, De Raedt R, Vanderhasselt MA, Baeken C. Influence of high-frequency repetitive transcanial magnetic stimulation over the dorsolateral prefrontal cortex on the inhibition of emotional information in healthy volunteers. Psychological Medicine: A Journal of Research in Psychiatry and the Allied Sciences. 2009;39(6):1019-28.
293 Li X, Nahas Z, Anderson B, Kozel FA, George MS. Can left prefrontal rTMS be used as a maintenance treatment for bipolar depression?. Depression and Anxiety. 2004;20(2):98-100. [pmid: 15390210].
294 Liang CS, Yang FW, Chiang KT, Ho PS. Allopurinol for treatment-resistant schizophrenia and epilepsy: A case report. Pharmacopsychiatry. 2010;43(6):233-4. [pmid: 20486042].
295 Linssen AC, Zitman FG. Patient evaluation of a cognitive behavioral group program for patients with chronic low back pain. Social Science & Medicine. 1984;19(12):1361-5. [pmid: 6241749].
296 Lisanby SH, Sampson S, Husain MM, Petrides G, Knapp RG, McCall V, et al. Toward individualized post-electroconvulsive therapy care: piloting the Symptom-Titrated, Algorithm-Based Longitudinal ECT (STABLE) intervention. Journal of ECT. Sep. 2008;24(3):179-82. [pmid: 18708943].
297 Loo C, Mitchell P, Sachdev P, McDarmont B, Parker G, Gandevia S. Double-blind controlled investigation of transcranial magnetic stimulation for the treatment of resistant major depression. American Journal of Psychiatry. Jun. 1999;156(6):946-8. [pmid: 10360138].
298 Loo CK, Sachdev P, Martin D, Pigot M, Alonzo A, Malhi GS, et al. A double-blind, sham-controlled trial of transcranial direct current stimulation for the treatment of depression. International Journal of Neuropsychopharmacology. 2010;13(1):61-9. [pmid: 19671217].
299 Luborzewski A, Regen F, Schindler F, Anghelescu I. Modafinil-Induced Reversible Hyperkinetic Nondystonic Movement Disorder in a Patient With Major Depressive Disorder. The Journal of Neuropsychiatry and Clinical Neurosciences. Spr. 2006;18(2):248-9. [pmid: 16720809].
300 MacDonald J, Rawkins S. Neutropenia due to nefazodone, interaction or coincidence?. Australian and New Zealand Journal of Psychiatry. 12. 2000;34(6):1031-2. [pmid: 11127614].
301 Mah L, Conn DK. Use of the D2/D3 receptor agonist pramipexole in treatment of rapid-cycling bipolar disorder in an elderly patient. The American Journal of Geriatric Psychiatry. 2010;18(3).
302 Mahgoub NA, Kotbi N. Acute depression and suicidal attempt following lowering the frequency of deep brain stimulation. The Journal of Neuropsychiatry and Clinical Neurosciences. 2009;21(4).
303 Maletzky B, McFarland B, Burt A. Refractory obsessive compulsive disorder and ECT. Convulsive Therapy. Mar. 1994;10(1):34-42. [pmid: 8055290].
304 Maluquer SS, Arranz B, San L. Depression improvement with calcium heparin. General Hospital Psychiatry. 11. 2002;24(6):450-1. [pmid: 12490350].
305 Mantovani A, Simpson HB, Fallon BA, Rossi S, Lisanby SH. Randomized sham-controlled trial of repetitive transcranial magnetic stimulation in treatment-resistant obsessive-compulsive disorder. International Journal of Neuropsychopharmacology. 2010;13(2):217-27. [pmid: 19691873].
306 Marazziti D, Ceraudo G, Consoli G. Effectiveness of duloxetine in a patient suffering from severe panic disorder. Clinical Neuropsychiatry: Journal of Treatment Evaluation. 2010;7(1):15-7.
307 Marazziti D, Dell'Osso B. Effectiveness of Risperidone in Psychogenic Stiff Neck. CNS Spectrums. 06. 2005;10(6):443-4. [pmid: 15908897].
308 Marazziti D, Golia F, Consoli G, Presta S, Pfanner C, Carlini M, et al. Effectiveness of long term augmentation with citalopram to clomipramine in treatment-resistance OCD patients. CNS Spectrums. 11. 2008;13(11):971-6. [pmid: 19037176].
309 Margoob MA, Ali Z, Andrade C. Efficacy of ECT in chronic, severe, antidepressant- and CBT-refractory PTSD: An open, prospective study. Brain Stimulation. 2010;3(1):28-35. [pmid: 20633428].
310 Maron E, Eller T, Vasar V, Nutt DJ. Effects of bupropion augmentation in escitalopram-resistant patients with major depressive disorder: An open-label, naturalistic study. Journal of Clinical Psychiatry. 2009;70(7):1054-6. [pmid: 19653982].
311 Marshall RD, Johannet CM, Collins PY, Smith H. Bupropion and sertraline combination treatment in refractory depression. Journal of Psychopharmacology. 1995;9(3):284-6.
312 Marshall RD, Liebowitz MR. Paroxetine/bupropion combination treatment for refractory depression. Journal of Clinical Psychopharmacology. 02. 1996;16(1):80-1. [pmid: 8834426].
313 Martin M, Crane C. Cognition and the body: Somatic attributions in irritable bowel syndrome. Behavioural and Cognitive Psychotherapy. Jan. 2003;31(1):13-31.
314 Martin PG, Butler JE, Gandevia SC, Taylor JL. Noninvasive stimulation of human corticospinal axons innervating leg muscles. Journal of Neurophysiology. Aug. 2008;100(2):1080-6. [pmid: 18509069].
315 Masaquel A, Wells K, Ettner SL. How does the persistence of depression influence the continuity and type of health insurance and coverage limits on mental health therapy?. Journal of Mental Health Policy and Economics. Sep. 2007;10(3):133-44. [pmid: 17890830].
316 Masdrakis VG, Florakis A, Tzanoulinos G, Markatou M, Oulis P. Safety of the electroconvulsive therapy-ziprasidone combination. The Journal of ECT. 2010;26(2):139-42. [pmid: 20386116].
317 Mathew SJ, Murrough JW, aan het Rot M, Collins KA, Reich DL, Charney DS. Riluzole for relapse prevention following intravenous ketamine in treatment-resistant depression: A pilot randomized, placebo-controlled continuation trial. International Journal of Neuropsychopharmacology. 2010;13(1):71-82. [pmid: 19288975].
318 Mattai A, Fung L, Bakalar J, Overman G, Tossell J, Miller R, et al. Adjunctive use of lithium carbonate for the management of neutropenia in clozapine-treated children. Human Psychopharmacology: Clinical and Experimental. 2009;24(7):584-9. [pmid: 19743394].
319 M'Bailara K, Van den Bulke D, Demazeau N, Demotes-Mainard J, Henry C. Depressive mixed state: Evidence for a new form of depressive state in type I and II bipolar patients. Neuropsychiatric Disease and Treatment. 2007;3(6):899-902. [pmid: 19300625].
320 McClintock SM, Cullum CM, Husain MM, Rush AJ, Knapp RG, Mueller M, et al. Evaluation of the effects of severe depression on global cognitive function and memory. CNS Spectrums. 2010;15(5):304-13. [pmid: 20448521].
321 McDonald WM, Easley K, Byrd EH, Holtzheimer P, Tuohy S, Woodard JL, et al. Combination rapid transcranial magnetic stimulation in treatment refractory depression. Neuropsychiatric Disease and Treatment. Jan. 2006;2(1):85-94. [pmid: 19412449].
322 McIntyre R, Katzman M. The role of atypical antipsychotics in bipolar depression and anxiety disorders. Bipolar Disorders. 12. 2003;5(2):20-35. [pmid: 14700010].
323 McLeod MN, Gaynes BN, Golden RN. Chromium potentiation of antidepressant pharmacotherapy for dysthymic disorder in 5 patients. Journal of Clinical Psychiatry. 04. 1999;60(4):237-40. [pmid: 10221284].
324 McLeod MN, Golden RN. Chromium treatment of depression. International Journal of Neuropsychopharmacology. 12. 2000;3(4):311-4. [pmid: 11343609].
325 McPherson S, Walker C, Caryle JA. Primary care counsellors' experiences of working with treatment resistant depression: A qualitative pilot study. Counselling & Psychotherapy Research. Dec. 2006;6(4):250-7.
326 Medda P, Perugi G, Zanello S, Ciuffa M, Cassano GB. Response to ECT in bipolar I, bipolar II and unipolar depression. Journal of Affective Disorders. 2009;118(1-3):55-9. [pmid: 19223079].
327 Medda P, Perugi G, Zanello S, Ciuffa M, Rizzato S, Cassano GB. Comparative response to electroconvulsive therapy in medication-resistant bipolar I patients with depression and mixed state. The Journal of ECT. 2010;26(2):82-6. [pmid: 19710623].
328 Menkes DL, Bodnar P, Ballesteros RA, Swenson MR. Right frontal lobe slow frequency repetitive transcranial magnetic stimulation (SF r-TMS) is an effective treatment for depression: A case-control pilot study of safety and efficacy. Journal of Neurology, Neurosurgery & Psychiatry. Jul. 1999;67(1):113-5.
329 Menza MA, Kaufman KR, Castellanos A. Modafinil augmentation of antidepressant treatment in depression. Journal of Clinical Psychiatry. 05. 2000;61(5):378-81. [pmid: 10847314].
330 Messer MM, Haller IV. Maintenance ketamine treatment produces long-term recovery from depression. Primary Psychiatry. 2010;17(4):48-50.
331 Michael A, Pallen A, Brown K. Lithium in resistant depression. Irish Journal of Psychological Medicine. May. 1992;9(1):71-2.
332 Michael N, Erfurth A, Ohrmann P, Arolt V, Heindel W, Pfleiderer B. Metabolic changes within the left dorsolateral prefrontal cortex occurring with electroconvulsive therapy in patients with treatment resistant unipolar depression. Psychological Medicine. 10. 2003;33(7):1277-84. [pmid: 14580081].
333 Michael N, Gösling M, Reutemann M, Kersting A, Heindel W, Arolt V, et al. Metabolic changes after repetitive transcranial magnetic stimulation (rTMS) of the left prefrontal cortex: a sham-controlled proton magnetic resonance spectroscopy (1H MRS) study of healthy brain. European Journal of Neuroscience. Jun. 2003;17(11):2462-8. [pmid: 12814378].
334 Mihara K, Nakamura A, Kuba T, Yakushi T, Hotta H, Kojima M, et al. Ropinirole augmentation therapy in a case with treatment-resistant unipolar depression. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 2010;34(4):703-4. [pmid: 20188777].
335 Miller IW, Bishop SB, Norman WH, Keitner GI. Cognitive/behavioural therapy and pharmacotherapy with chronic, drug-refractory depressed inpatients: A note of optimism. Behavioural Psychotherapy. Oct. 1985;13(4):320-7.
336 Montenegro MA, Guerreiro MM, Scotoni AE, Stella F, Leone AaAA, Honorato DC, et al. De novo psychogenic seizures after epilepsy surgery: case report. Arquivos de Neuro-Psiquiatria. Jun. 2000;58(2):535-7. [pmid: 10920419].
337 Moreno FA, Gelenberg AJ, Bachar K, Delgado PL. Pindolol augmentation of treatment-resistant depressed patients. Journal of Clinical Psychiatry. 10. 1997;58(10):437-9. [pmid: 9375594].
338 Morgan JF, Crisp AH. Use of leukotomy for intractable anorexia nervosa: A long-term follow-up study. International Journal of Eating Disorders. Apr. 2000;27(3):249-58. [pmid: 10694710].
339 Morishita S, Aoki S. Clonazepam in the treatment of prolonged depression. Journal of Affective Disorders. 06. 1999;53(3):275-8. [pmid: 10404714].
340 Morishita S, Arita S. Lithium Augmentation of Antidepressants in the Treatment of Protracted Depression. International Medical Journal. 03. 2003;10(1):29-32.
341 Morishita S, Sonohara M, Murakami H, Matsushita K, Ebata J, Koshikawa T, et al. Vitamin E treatment of prolonged depression: A report of nine cases. International Medical Journal. 03. 2000;7(1):33-6.
342 Moscrip TD, Terrace HS, Sackeim HA, Lisanby SH. Randomized controlled trial of the cognitive side-effects of magnetic seizure therapy (MST) and electroconvulsive shock (ECS). International Journal of Neuropsychopharmacology. Feb. 2006;9(1):1-11. [pmid: 16045810].
343 Mottaghy FM, Keller CE, Gangitano M, Ly J, Thall M, Parker JA, et al. Correlation of cerebral blood flow and treatment effects of repetitive transcranial magnetic stimulation in depressed patients. Psychiatry Research: Neuroimaging. Aug. 2002;115(1):1-14.
344 Mueller PS, Albin SM, Barnes RD, Rasmussen KG Jr. Safety of electroconvulsive therapy in patients With unrepaired abdominal aortic aneurysm: Report of 8 patients. The Journal of ECT. 2009;25(3):165-9. [pmid: 19730028].
345 Müller JF, Orekhov Y, Liu Y, Ziemann U. Homeostatic plasticity in human motor cortex demonstrated by two consecutive sessions of paired associative stimulation. European Journal of Neuroscience. Jun. 2007;25(11):3461-8. [pmid: 17553015].
346 Müller K, Fabó D, Entz L, Kelemen A, Halász P, Rásonyi G, et al. Outcome of vagus nerve stimulation for epilepsy in Budapest. Epilepsia. 2010;51(Suppl 3):98-101.
347 Müller UJ, Sturm V, Voges J, Heinze HJ, Galazky I, Heldmann M, et al. Successful treatment of chronic resistant alcoholism by deep brain stimulation of nucleus accumbens: First experience with three cases. Pharmacopsychiatry. 2009;42(6):288-91. [pmid: 19924591].
348 Müller-Dahlhaus JF, Liu Y, Ziemann U. Interindividual variability and age-dependency of motor cortical plasticity induced by paired associative stimulation. Experimental Brain Research. May. 2008;187(3):467-75.
349 Münchau A, Bloem BR, Thilo KV, Trimble MR, Rothwell JC, Robertson MM. Repetitive transcranial magnetic stimulation for Tourette syndrome. Neurology. Dec. 2002;59(11):1789-91. [pmid: 12473773].
350 Münchau A, Langosch JM, Gerschlager W, Rothwell JC, Orth M, Trimble MR. Mirtazapine increases cortical excitability in healthy controls and epilepsy patients with major depression. Journal of Neurology, Neurosurgery & Psychiatry. Apr. 2005;76(4):527-33.
351 Murakami T, Sakuma K, Nomura T, Uemura Y, Hashimoto I, Nakashima K. Changes in somatosensory-evoked potentials and high-frequency oscillations after paired-associative stimulation. Experimental Brain Research. Jan. 2008;184(3):339-47.
352 Nagler J. Absence of asystole during bifrontal stimulation in electroconvulsive therapy. The Journal of ECT. 2010;26(2):100-3. [pmid: 19935092].
353 Nahas Z, Anderson BS, Borckardt J, Arana AB, George MS, Reeves ST, et al. Bilateral epidural prefrontal cortical stimulation for treatment-resistant depression. Biological Psychiatry. 2010;67(2):101-9. [pmid: 19819427].
354 Nahas Z, Bohning DE, Molloy MA, Oustz JA, Risch SC, George MS. Safety and feasibility of repetitive transcranial magnetic stimulation in the treatment of anxious depression in pregnancy: A case report. Journal of Clinical Psychiatry. Jan. 1999;60(1):50-2. [pmid: 10074879].
355 Nahas Z, Teneback CC, Kozel A, Speer AM, DeBrux C, Molloy M, et al. Brain effects of TMS delivered over prefrontal cortex in depressed adults: Role of stimulation frequency and coil-cortex distance. Journal of Neuropsychiatry & Clinical Neurosciences. Fal. 2001;13(4):459-70. [pmid: 11748315].
356 Nakajima S, Ishida T, Akaishi R, Takahata K, Kitahata R, Uchida H, et al. Impacts of switching antidepressants after successful electroconvulsive therapy on the maintenance of clinical remission in patients with treatment-resistant depression: A chart review. The Journal of ECT. 2009;25(3):178-81. [pmid: 19710625].
357 Neuner I, Halfter S, Wollenweber F, Podoll K, Schneider F. Nucleus accumbens deep brain stimulation did not prevent suicide attempt in Tourette syndrome. Biological Psychiatry. 2010;68(4):e19-e20. [pmid: 20385371].
358 Ng RMK. Cognitive Therapy for Obsessive-compulsive Personality Disorder - A Pilot Study in Hong Kong Chinese Patients. Hong Kong J Psychiatry. Jun. 2005;15(2):50-3.
359 Ng RMK, Hui LK, Pau L. Cognitive-behavioural therapy by novices for supervised community hostel residents with treatment-resistant schizophrenia in Hong Kong: A pilot study. Hong Kong J Psychiatry. Jun. 2008;18(2):49-54.
360 Nicolato R, Dias FvF, Salgado JoVc, Cardoso Vale RD, Teixeira AnLc. Diagnostic and therapeutic challenges involving patients with post-traumatic stress disorder and schizoaffective disorder depressive type. Acta Neuropsychiatrica. 02. 2009;21(1):47-8.
361 Nierenberg AA, Fava M, Trivedi MH, Wisniewski SR, Thase ME, McGrath PJ, et al. Comparison of Lithium and T(3) Augmentation Following Two Failed Medication Treatments for Depression: A STAR*D Report. The American Journal of Psychiatry. 09. 2006;163(9):1519-30. [pmid: 16946176].
362 Nilsson BM, Ekselius L. Acute and maintenance electroconvulsive therapy for treatment of severely disabling obsessive-compulsive symptoms in a patient with Asperger Syndrome. The Journal of ECT. 2009;25(3):205-7. [pmid: 19384252].
363 No authorship i. Feature Interview: David Avery, MD on Transcranial Magnetic Stimulation for depression. Essential Psychopharmacology. 2004;5(4):307-14.
364 No authorship i. Botox treatment of depression. Primary Psychiatry. Jul. 2006;13(7):26-7.
365 Noble JM. Religious coping styles, perceived stress, depression, and professional psychological help-seeking attitudes among African American women. Dissertation Abstracts International Section A: Humanities and Social Sciences. Apr. 1998;58(10):3743.
366 Nordanskog P, Dahlstrand U, Larsson MR, Larsson EM, Knutsson L, Johanson A. Increase in hippocampal volume after electroconvulsive therapy in patients with depression: A volumetric magnetic resonance imaging study. The Journal of ECT. 2010;26(1):62-7. [pmid: 20190603].
367 Ntatsaki E, D'Mello O, Lewis J, Underwood BR, Smith M, Head L. Electroconvulsive treatment for a patient with psychotic depression and inclusion body myositis. The Journal of ECT. 2009;25(2):125-8. [pmid: 18708945].
368 Oathes DJ, Bruce JM, Nitschke JB. Worry facilitates corticospinal motor response to transcranial magnetic stimulation. Depression and Anxiety. 2008;25(11):969-76. [pmid: 18046733].
369 O'Connor DW, Gardner B, Presnell I, Singh D, Tsanglis M, White E. The effectiveness of continuation-maintenance ECT in reducing depressed older patients' hospital re-admissions. Journal of Affective Disorders. 2010;120(1-3):62-6. [pmid: 19411112].
370 Ogden M, Lyndon W, Pridmore S. Repetitive transcranial magnetic stimulation (rTMS) in major depressive episode with postpartum onset: A case study. German J Psychiatry. 1999;2(1):43-5.
371 Okada F, Okajima K. Violent acts associated with fluvoxamine treatment. Journal of Psychiatry & Neuroscience. 2001;26(4):339-40. [pmid: 11590975].
372 Okamoto N, Furusawa Y, Sakamoto K, Yamamoto T, Kondo Y, Nagafusa Y, et al. Major depression: What caused the crisis. The Lancet. 2010;375(9711).
373 Okamoto N, Nakai T, Sakamoto K, Nagafusa Y, Higuchi T, Nishikawa T. Rapid antidepressant effect of ketamine anesthesia during electroconvulsive therapy of treatment-resistant depression: Comparing ketamine and propofol anesthesia. The Journal of ECT. 2010;26(3):223-7. [pmid: 19935085].
374 Okamoto N, Sakamoto K, Nagafusa Y, Ichikawa M, Nakai T, Higuchi T. Electroconvulsive therapy as a potentially effective treatment for severe serotonin syndrome: Two case reports. Journal of Clinical Psychopharmacology. 2010;30(3):350-1. [pmid: 20473084].
375 Okazaki M, Tominaga K, Higuchi H, Utagawa I, Nakamura E, Noguchi M, et al. Predictors of response to electroconvulsive therapy obtained using the three-factor structure of the Montgomery and Åsberg Depression Rating Scale for treatment-resistant depressed patients. The Journal of ECT. 2010;26(2):87-90. [pmid: 19710622].
376 O'Reardon JP, Blumner KH, Peshek AD, Pradilla RR, Pimiento PC. Long-Term Maintenance Therapy for Major Depressive Disorder With rTMS. Journal of Clinical Psychiatry. Dec. 2005;66(12):1524-8. [pmid: 16401152].
377 O'Reardon JP, Fontecha JF, Cristancho MA, Newman S. Unexpected reduction in migraine and psychogenic headaches following rTMS treatment for major depression: A report of two cases. CNS Spectrums. Dec. 2007;12(12):921-5. [pmid: 18163038].
378 Ostroff RB, Nelson JC. Risperidone augmentation of selective serotonin reuptake inhibitors in major depression. Journal of Clinical Psychiatry. 04. 1999;60(4):256-9. [pmid: 10221288].
379 Oulis P, Kokras N, Papadimitriou GN, Masdrakis VG. Adjunctive low-dose amisulpride in motor conversion disorder. Clinical neuropharmacology. 2009;32(6):342-3. [pmid: 19952874].
380 Pérez V, Soler J, Puidgemont D, Alvarez E, Artigas F. A double-blind, randomized, placebo-controlled trial of pindolol augmentation in depressive patients resistant to serotonin reuptake inhibitors. Archives of General Psychiatry. 04. 1999;56(4):375-9. [pmid: 10197835].
381 Padberg F, di Michele F, Zwanzger P, Romeo E, Bernardi G, Schüle C, et al. Plasma concentrations of neuroactive steroids before and after repetitive transcranial magnetic stimulation (rTMS) in major depression. Neuropsychopharmacology. Nov. 2002;27(5):874-8. [pmid: 12431862].
382 Padberg F, di Michele F, Zwanzger P, Romeo E, Bernardi G, Schüle C, et al. Plasma concentrations of neuroactive steroids before and after repetitive transcranial magnetic stimulation in depression: Correction. Neuropsychopharmacology. Mar. 2003;28(3):610-1.
383 Palmio J, Huuhka M, Laine S, Huhtala H, Peltola J, Leinonen E, et al. Electroconvulsive therapy and biomarkers of neuronal injury and plasticity: Serum levels of neuron-specific enolase and S-100b protein. Psychiatry Research. 2010;177(1-2):97-100. [pmid: 20378182].
384 Papakostas GI, Petersen T, losifescu DV, Burns AM, Nierenberg AA, Alpert JE, et al. Obesity among outpatients with major depressive disorder. International Journal of Neuropsychopharmacology. 03. 2005;8(1):59-63. [pmid: 15361263].
385 Papakostas GI, Petersen T, Mischoulon D, Hughes ME, Spector AR, Alpert JE, et al. Functioning and interpersonal relationships as predictors of response in treatment-resistant depression. Comprehensive Psychiatry. 01. 2003;44(1):44-50. [pmid: 12524635].
386 Papakostas GI, Petersen T, Pava J, Masson E, Worthington JJ III, Alpert JE, et al. Hopelessness and Suicidal Ideation in Outpatients With Treatment- Resistant Depression: Prevalence and Impact on Treatment Outcome. Journal of Nervous and Mental Disease. 07. 2003;191(7):444-9. [pmid: 12891091].
387 Papakostas GI, Petersen T, Sonawalla SB, Merens W, Iosifescu DV, Alpert JE, et al. Serum cholesterol in treatment-resistant depression. Neuropsychobiology. 2003;47(3):146-51. [pmid: 12759558].
388 Papakostas GI, Petersen TJ, Kinrys G, Burns AM, Worthington JJ III, Alpert JE, et al. Aripiprazole Augmentation of Selective Serotonin Reuptake Inhibitors for Treatment-Resistant Major Depressive Disorder. Journal of Clinical Psychiatry. 10. 2005;66(10):1326-30. [pmid: 16259548].
389 Papakostas GI, Petersen TJ, Nierenberg AA, Murakami JL, Alpert JE, Rosenbaum JF, et al. Ziprasidone augmentation of selective serotonin reuptake inhibitors (SSRIs) for SSRI-resistant major depressive disorder. Journal of Clinical Psychiatry. 02. 2004;65(2):217-21. [pmid: 15003076].
390 Parker G, Brotchie H. Do the old psychostimulant drugs have a role in managing treatment-resistant depression?. Acta Psychiatrica Scandinavica. 2010;121(4):308-14. [pmid: 19594481].
391 Parker G, Watkins T. Treatment-resistant depression: When antidepressant drug intolerance may indicate food intolerance. Australian and New Zealand Journal of Psychiatry. 04. 2002;36(2):263-5. [pmid: 11982551].
392 Paslakis G, Gilles M, Deuschle M. Clinically relevant pharmacokinetic interaction between venlafaxine and bupropion: A case series. Journal of Clinical Psychopharmacology. 2010;30(4):473-4. [pmid: 20631572].
393 Pasquini M, Berardelli I, Biondi M. Amantadine augmentation for refractory obsessive-compulsive disorder: A case report. Journal of Clinical Psychopharmacology. 2010;30(1):85-6. [pmid: 20075660].
394 Pathak S, Johns ES, Kowatch RA. Adjunctive Quetiapine for Treatment-Resistant Adolescent Major Depressive Disorder: A Case Series. Journal of Child and Adolescent Psychopharmacology. Sep. 2005;15(4):696-702. [pmid: 16190801].
395 Patkar AA, Masand PS, Pae CU, Peindl K, Hooper-Wood C, Mannelli P, et al. A Randomized, Double-blind, Placebo-controlled Trial of Augmentation with an Extended Release Formulation of Methylphenidate in Outpatients with Treatment-Resistant Depression. Journal of Clinical Psychopharmacology. 12. 2006;26(6):653-6. [pmid: 17110825].
396 Peet M, Horrobin DF. A dose-ranging study of the effects of ethyl-eicosapentaenoate in patients with ongoing depression despite apparently adequate treatment with standard drugs. Archives of General Psychiatry. 10. 2002;59(10):913-20. [pmid: 12365878].
397 Perez MA, Lundbye-Jensen J, Nielsen JB. Task-specific depression of the soleus H-reflex after contraction training of antagonistic ankle muscles. Journal of Neurophysiology. Dec. 2007;98(6):3677-87. [pmid: 17942616].
398 Perkins C Jr. Aripiprazole effective as adjunct to antidepressant therapy in patients with major depressive disorder. Primary Psychiatry. 07. 2007;14(7):18.
399 Perretti A, Balbi P, Orefice G, Trojano L, Marcantonio L, Brescia-Morra V, et al. Post-exercise facilitation and depression of motor evoked potentials to transcranial magnetic stimulation: A study in multiple sclerosis. Clinical Neurophysiology. Sep. 2004;115(9):2128-33. [pmid: 15294215].
400 Perugi G, Frare F, Toni C, Tusini G, Vannucchi G, Akiskal HS. Adjunctive valproate in panic disorder patients with comorbid bipolar disorder or otherwise resistant to standard antidepressants: A 3-year “open” follow-up study. European Archives of Psychiatry and Clinical Neuroscience. 2010;260(7):553-60. [pmid: 20238120].
401 Pesiridou A, Baquero G, Cristancho P, Wakil L, Altinay M, Kim D, et al. A case of delayed onset of threatened premature labor in association with electroconvulsive therapy in the third trimester of pregnancy. The Journal of ECT. 2010;26(3):228-30. [pmid: 20375702].
402 Petajan JH, White AT. Motor-evoked potentials in response to fatiguing grip exercise in multiple sclerosis patients. Clinical Neurophysiology. Dec. 2000;111(12):2188-95. [pmid: 11090771].
403 Petersen T, Hughes M, Papakostas GI, Kant A, Fava M, Rosenbaum JF, et al. Treatment-resistant depression and Axis II comorbidity. Psychotherapy and Psychosomatics. Sep-Oct. 2002;71(5):269-74. [pmid: 12207107].
404 Petersen T, Papakostas GI, Mahal Y, Guyker WM, Beaumont EC, Alpert JE, et al. Psychosocial functioning in patients with treatment resistant depression. European Psychiatry. 06. 2004;19(4):196-201. [pmid: 15196600].
405 Peterson TJ, Feldman G, Harley R, Fresco DM, Graves L, Holmes A, et al. Extreme response style in recurrent and chronically depressed patients: Change with antidepressant administration and stability during continuation treatment. Journal of Consulting and Clinical Psychology. Feb. 2007;75(1):145-53. [pmid: 17295573].
406 Phelps LE, Brutsche N, Moral JR, Luckenbaugh DA, Manji HK, Zarate CA Jr. Family history of alcohol dependence and initial antidepressant response to an N-methyl-D-aspartate antagonist. Biological Psychiatry. 01. 2009;65(2):181-4. [pmid: 18996507].
407 Philip NS, Carpenter LL, Tyrka AR, Price LH. Using atypical antipsychotics to augment treatment of nonpsychotic unipolar major depression. Directions in Psychiatry. 2009;29(1):51-8.
408 Philip NS, Carpenter LL, Tyrka AR, Whiteley LB, Price LH. Varenicline augmentation in depressed smokers: An 8-week, open-label study. Journal of Clinical Psychiatry. 07. 2009;70(7):1026-31. [pmid: 19323966].
409 Picardi A, Di Gennaro G, Meldolesi GN, Grammaldo LG, Esposito V, Quarato PP. Partial Seizures due to Sclerosis of the Right Amygdala Presenting as Panic Disorder. Psychopathology. 2007;40(3):178-83. [pmid: 17337938].
410 Piccinni A, Del Debbio A, Medda P, Bianchi C, Roncaglia I, Veltri A, et al. Plasma brain-derived neurotrophic factor in treatment-resistant depressed patients receiving electroconvulsive therapy. European Neuropsychopharmacology. 05. 2009;19(5):349-55. [pmid: 19223156].
411 Pieroni S, McShane R. Effect of an educational video on the accuracy of surrogate decisions: The case of electroconvulsive therapy. The Journal of ECT. 2010;26(3):208-12. [pmid: 20386462].
412 Pilhatsch MK, Burghardt R, Wandinger KP, Bauer M, Adli M. Augmentation with atomoxetine in treatment-resistant depression with psychotic features: A case report. Pharmacopsychiatry. 03. 2006;39(2):79-80. [pmid: 16555170].
413 Pinto A, La Pia S, Mennella R, Giorgio D, DeSimone L. Cognitive-behavioral therapy and clozapine for clients with treatment-refractory schizophrenia. Psychiatric Services. Jul. 1999;50(7):901-4. [pmid: 10402608].
414 Pitcher JB, Ridding MC, Miles TS. Frequency-dependent, bi-directional plasticity in motor cortex of human adults. Clinical Neurophysiology. Jul. 2003;114(7):1265-71. [pmid: 12842724].
415 Pogarell O, Koch W, Pöpperl G, Tatsch K, Jakob F, Zwanzger P, et al. Striatal dopamine release after prefrontal repetitive transcranial magnetic stimulation in major depression: preliminary results of a dynamic [123I] IBZM SPECT study. Journal of Psychiatric Research. Jun. 2006;40(4):307-14. [pmid: 16259998].
416 Pomara N, Gershon S. Treatment-resistant depression in an elderly patient with pancreatic carcinoma: Case report. Journal of Clinical Psychiatry. 10. 1984;45(10):439-40. [pmid: 6480571].
417 Poon DE, Roy FD, Gorassini MA, Stein RB. Interaction of paired cortical and peripheral nerve stimulation on human motor neurons. Experimental Brain Research. Jun. 2008;188(1):13-21.
418 Porta M, Brambilla A, Cavanna AE, Servello D, Sassi M, Rickards H, et al. Thalamic deep brain stimulation for treatment-refractory Tourette syndrome: Two-year outcome. Neurology. 2009;73(17):1375-80. [pmid: 19858459].
419 Porter R, Booth D, Gray H, Frampton C. Effects of the addition of remifentanil to propofol anesthesia on seizure length and postictal suppression index in electroconvulsive therapy. Journal of ECT. Sep. 2008;24(3):203-7. [pmid: 18772705].
420 Poulet E, Brunelin J, Ben Makhlouf W, D'Amato T, Saoud M. A case report of cTBS for the treatment of auditory hallucinations in a patient with schizophrenia. Brain Stimulation. 2009;2(2):118-9. [pmid: 20633409].
421 Prakash J, Kotwal A, Prabhu HRA. Therapeutic and Prophylactic Utility of the Memory-Enhancing Drug Donepezil Hydrochloride on Cognition of Patients Undergoing Electroconvulsive Therapy: A Randomized Controlled Trial. Journal of ECT. Sep. 2006;22(3):163-8. [pmid: 16957530].
422 Preskorn SH. Polypharmacy in a patient with refractory major depression. Part I: The case. Journal of Psychiatric Practice. 11. 2002;8(6):370-6. [pmid: 15985903].
423 Preskorn SH. Polypharmacy in a case of refractory major depression: Part II: Implications for clinical management. Journal of Psychiatric Practice. 01. 2003;9(1):71-8. [pmid: 15985916].
424 Price RB, Shungu DC, Mao X, Nestadt P, Kelly C, Collins KA, et al. Amino acid neurotransmitters assessed by proton magnetic resonance spectroscopy: Relationship to treatment resistance in major depressive disorder. Biological Psychiatry. 05. 2009;65(9):792-800. [pmid: 19058788].
425 Pridmore S, Bruno R, Turnier-Shea Y, Reid P, Rybak M. Comparison of unlimited numbers of rapid transcranial magnetic stimulation (rTMS) and ECT treatment sessions in major depressive episode. International Journal of Neuropsychopharmacology. Jun. 2000;3(2):129-34. [pmid: 11343589].
426 Pridmore S, Poxon M, Chan C. Longer than expected course of transcranial magnetic stimulation. Australian and New Zealand Journal of Psychiatry. Feb. 1998;32(1):140. [pmid: 9565198].
427 Pridmore S, Rybak M, Turnier-Shea Y, Reid P, Bruno PR, Couper D. A naturalistic study of response in melancholia to transcranial magnetic stimulation (TMS). German Journal of Psychiatry. 1999;2(1):13-21.
428 Puri BK, Counsell SJ, Richardson AJ, Horrobin DF. Eicosapentaenoic acid in treatment-resistant depression. Archives of General Psychiatry. 01. 2002;59(1):91-2. [pmid: 11779290].
429 Quitkin F, McGrath PJ, Stewart JW, Ocepek-Welikson K, Taylor BP, Nunes E, et al. Chronological milestones to guide drug change: When should clinicians switch antidepressants?. Archives of General Psychiatry. 09. 1996;53(9):785-92. [pmid: 8792755].
430 Raja M. Delayed loss of efficacy and depressogenic action of antidepressants. Journal of Clinical Psychopharmacology. 2009;29(6):612-4. [pmid: 19910735].
431 Rasmussen KG, Stevens SR, Kung S, Mohan A. Melancholic symptoms as assessed by the Hamilton Depression Rating Scale and outcomes with and without electroconvulsive therapy on an in-patient mood disorders unit. Acta Neuropsychiatrica. 2010;22(1):21-5.
432 Reda MA, Carpiniello B, Secchiaroli L, Blanco S. Thinking, depression, and antidepressants: Modified and unmodified depressive beliefs during treatment with amitriptyline. Cognitive Therapy and Research. Apr. 1985;9(2):135-43.
433 Reid P, Pridmore S. Improvement in chronic pain with transcranial magnetic stimulation. Australian and New Zealand Journal of Psychiatry. Apr. 2001;35(2):252. [pmid: 11284914].
434 Reid PD, Daniels B, Rybak M, Turnier-Shea Y, Pridmore S. Cortical excitability of psychiatric disorders: Reduced post-exercise facilitation in depression compared to schizophrenia and controls. Australian and New Zealand Journal of Psychiatry. Oct. 2002;36(5):669-73. [pmid: 12225452].
435 Reid PD, Pridmore S. Dexamethasone suppression test reversal in rapid transcranial magnetic stimulation-treated depression. Australian and New Zealand Journal of Psychiatry. Apr. 1999;33(2):274-7. [pmid: 10336227].
436 Reif A, Leonhard C, Mössner R, Lesch KP, Fallgatter AJ. Encephalopathy and myoclonus triggered by valproic acid. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 09. 2004;28(6):1061-3. [pmid: 15380868].
437 Richter J, Möller B, Spitzer C, Letzel S, Bartols S, Barnow S, et al. Transcallosal inhibition in patients with and without alexithymia. Neuropsychobiology. Apr. 2006;53(2):101-7. [pmid: 16557040].
438 Rim CL, Gitlin MJ. Ziprasidone, monoamine oxidase inhibitors, and the serotonin syndrome. Journal of Clinical Psychopharmacology. 2010;30(4):470-1. [pmid: 20631570].
439 Riva G, Bacchetta M, Cesa G, Conti S, Molinari E. Six-Month Follow-Up of In-Patient Experiential Cognitive Therapy for Binge Eating Disorders. CyberPsychology & Behavior. Jun. 2003;6(3):251-8. [pmid: 12855080].
440 Rollnik JD, Huber TJ, Mogk H, Siggelkow S, Kropp S, Dengler R, et al. High frequency repetitive transcranial magnetic stimulation (rTMS) of the dorsolateral prefrontal cortex in schizophrenic patients. Neuroreport: For Rapid Communication of Neuroscience Research. Dec. 2000;11(18):4013-5.
441 Ropohl A, Hiller M, Elstner S, Sperling W, Kornhuber J, Bickel A. Dental pain during repetitive transcranial magnetic stimulation. European Psychiatry. Nov. 2004;19(7):457-8. [pmid: 15504662].
442 Rosa MA, Picarelli H, Teixeira MJ, Rosa MO, Marcolin MA. Accidental seizure with repetitive transcranial magnetic stimulation. Journal of ECT. Dec. 2006;22(4):265-6. [pmid: 17143158].
443 Rosenhagen MC, Uhr M. Single nucleotide polymorphism in the drug transporter gene ABCB1 in treatment-resistant depression: Clinical practice. Journal of Clinical Psychopharmacology. 2010;30(2):209-11. [pmid: 20520302].
444 Rosenkranz K, Williamon A, Rothwell JC. Motorcortical excitability and synaptic plasticity is enhanced in professional musicians. Journal of Neuroscience. May. 2007;27(19):5200-6. [pmid: 17494706].
445 Rothbaum BO, Killeen TK, Davidson JRT, Brady KT, Connor KM, Heekin MH. Placebo-controlled trial of risperidone augmentation for selective serotonin reuptake inhibitor-resistant civilian posttraumatic stress disorder. Journal of Clinical Psychiatry. 04. 2008;69(4):520-5. [pmid: 18278987].
446 Rothschild AJ. The diagnosis and treatment of late-life depression. Journal of Clinical Psychiatry. 1996;57(5):5-11. [pmid: 8647792].
447 Rush AJ, Kilner J, Fava M, Wisniewski SR, Warden D, Nierenberg AA, et al. Clinically relevant findings from STAR*D. Psychiatric Annals. 03. 2008;38(3):188-93.
448 Russell JC, Rasmussen KG, O'Connor MK, Copeman CA, Ryan DA, Rummans TA. Long-term maintenance ECT: A retrospective review of efficacy and cognitive outcome. Journal of ECT. 2003;19(1):4-9. [pmid: 12621270].
449 Ruzek JI, Riney SJ, Leskin G, Drescher KD, Foy DW, Gusman FD. Do post-traumatic stress disorder symptoms worsen during trauma focus group treatment?. Military Medicine. Oct. 2001;166(10):898-902. [pmid: 11603243].
450 Rybak M, Bruno R, Turnier-Shea Y, Pridmore S. An attempt to increase the rate and magnitude of the antidepressant effect of transcranial magnetic stimulation (TMS) a pilot study. German Journal of Psychiatry. 2005;8(4):59-65.
451 Rybakowski JK, Angst J, Dudek D, Pawlowski T, Lojko D, Siwek M, et al. Polish version of the Hypomania Checklist (HCL-32) scale: The results in treatment-resistant depression. European Archives of Psychiatry and Clinical Neuroscience. 2010;260(2):139-44. [pmid: 19557301].
452 Saba G, Verdon CM, Kalalou K, Rocamora JF, Dumortier G, Benadhira R, et al. Transcranial magnetic stimulation in the treatment of schizophrenic symptoms: A double blind sham controlled study. Journal of Psychiatric Research. Mar. 2006;40(2):147-52. [pmid: 15964595].
453 Sachdev PS, Loo CK, Mitchell PB, McFarquhar TF, Malhi GS. Repetitive transcranial magnetic stimulation for the treatment of obsessive compulsive disorder: A double-blind controlled investigation. Psychological Medicine. Nov. 2007;37(11):1645-9. [pmid: 17655805].
454 Sachsse U, Vogel C, Leichsenring F. Results of psychodynamically oriented trauma-focused inpatient treatment for women with complex posttraumatic stress disorder (PTSD) and borderline personality disorder (BPD). Bulletin of the Menninger Clinic. Spr. 2006;70(2):125-44. [pmid: 16753036].
455 Saijo T, Takano A, Suhara T, Arakawa R, Okumura M, Ichimiya T, et al. Effect of electroconvulsive therapy on 5-HT[sub]1A[/sub] receptor binding in patients with depression: A PET study with [^11^C]WAY 100635. International Journal of Neuropsychopharmacology. 2010;13(6):785-91. [pmid: 20067660].
456 Sakkas P, Mihalopoulou P, Mourtzouhou P, Psarros C, Masdrakis V, Politis A, et al. Induction of mania by rTMS: report of two cases. European Psychiatry. Jun. 2003;18(4):196-8. [pmid: 12814856].
457 Sakkas P, Psarros C, Papadimitriou GN, Theleritis CG, Soldatos CR. Repetitive transcranial magnetic stimulation (rTMS) in a patient suffering from comorbid depression and panic disorder following a myocardial infarction. Progress in Neuro-Psychopharmacology & Biological Psychiatry. Jul. 2006;30(5):960-2. [pmid: 16631291].
458 Salloum IM, Cornelius JR, Thase ME, Daley DC, Kirisci L, Spotts C. Naltrexone utility in depressed alcoholics. Psychopharmacology Bulletin. 1998;34(1):111-5. [pmid: 9564207].
459 Samii A, Wassermann EM, Hallett M. Post-exercise depression of motor evoked potentials as a function of exercise duration. Electroencephalography & Clinical Neurophysiology: Electromyography & Motor Control. Oct. 1997;105(5):352-6.
460 Samii A, Wassermann EM, Ikoma K, Mercurim B. Decreased postexercise facilitation of motor evoked potentials in patients with chronic fatigue syndrome or depression. Neurology. Dec. 1996;47(6):1410-4. [pmid: 8960719].
461 Santoro A, Florita M, Rossini D, Benedetti F, Lucca A. The processing of emotional stimuli in subjects with a major depression episode treated with rTMS. Clinical Neuropsychiatry: Journal of Treatment Evaluation. Jun. 2005;2(3):183-8.
462 Sarkhel S, Sinha VK, Praharaj SK. Adjunctive high-frequency right prefrontal repetitive transcranial magnetic stimulation (rTMS) was not effective in obsessive–compulsive disorder but improved secondary depression. Journal of Anxiety Disorders. 2010;24(5):535-9. [pmid: 20392594].
463 Sartorius A, Kiening KL, Kirsch P, von Gall CC, Haberkorn U, Unterberg AW, et al. Remission of major depression under deep brain stimulation of the lateral habenula in a therapy-refractory patient. Biological Psychiatry. 2010;67(2):e9-e11. [pmid: 19846068].
464 Schlaepfer TE, Cohen MX, Frick C, Kosel M, Brodesser D, Axmacher N, et al. Deep brain stimulation to reward circuitry alleviates anhedonia in refractory major depression. Neuropsychopharmacology. Jan. 2008;33(2):368-77. [pmid: 17429407].
465 Schneier FR, Belzer KD, Kishon R, Amsel L, Simpson HB. Escitalopram for persistent symptoms of generalized anxiety disorder after CBT: A pilot study. Journal of Nervous and Mental Disease. 2010;198(6):458-61. [pmid: 20531128].
466 Schrader GD, Levien HE. Response to sequential administration of clomipramine and lithium carbonate in treatment-resistant depression. British Journal of Psychiatry. 11. 1985;147:573-5. [pmid: 3935196].
467 Schramm E, Schneider D, Zobel I, van Calker D, Dykierek P, Kech S, et al. Efficacy of interpersonal psychotherapy plus pharmacotherapy in chronically depressed inpatients. Journal of Affective Disorders. Jul. 2008;109(1):65-73. [pmid: 18067973].
468 Schutter DJLG, van Honk J, Laman M, Vergouwen AC, Koerselman F. Increased sensitivity for angry faces in depressive disorder following 2 weeks of 2-Hz repetitive transcranial magnetic stimulation to the right parietal cortex. International Journal of Neuropsychopharmacology. 2010;13(9):1155-61. [pmid: 20587129].
469 Schwartz TL, Costello A. Charting a sustained response to vagus nerve stimulation in treatment-resistant major depressive disorder. Primary Psychiatry. Aug. 2007;14(8):66-8.
470 Scocco P, Frank E. Interpersonal psychotherapy as augmentation treatment in depressed elderly responding poorly to antidepressant drugs: A case series. Psychotherapy and Psychosomatics. Nov-Dec. 2002;71(6):357-61. [pmid: 12411771].
471 Seidman SN, Miyazaki M, Roose SP. Intramuscular testosterone supplementation to selective serotonin reuptake inhibitor in treatment-resistant depressed men: Randomized placebo-controlled clinical trial. Journal of Clinical Psychopharmacology. 12. 2005;25(6):584-8. [pmid: 16282843].
472 Sengul C, Kalkancý Ö, Simsek D, Herken H. Maintenance electroconvulsive therapy combined with long-acting risperidone in the treatment of resistant bipolar affective disorder. The Journal of ECT. 2009;25(4):282-3. [pmid: 19440160].
473 Serby M. Methylphemdate-Induced Obsessive-Compulsive Symptoms in an Elderly Man. CNS Spectrums. 08. 2003;8(8):612-3. [pmid: 12907924].
474 Serby MJ, Lantz M, Chabus BI, Bernay LJ. Takotsubo cardiomyopathy and electroconvulsive treatments: A case study and review. International Journal of Psychiatry in Medicine. 2010;40(1):93-6. [pmid: 20565047].
475 Seymour J, Wattis JP. Treatment resistant depression in the elderly: Three cases. International Clinical Psychopharmacology. Spr. 1992;7(1):55-7. [pmid: 1624758].
476 Shah A. The impact of the National Institute of Clinical Excellence guidance on the use of electroconvulsive therapy in England. International Psychogeriatrics. 2010;22(1):164-6. [pmid: 19691910].
477 Shajahan PM, Glabus MF, Jenkins JA, Ebmeier KP. Postexercise motor evoked potentials in depressed and recovered depressed patients, and controls. Neurology. Aug. 1999;53(3):644-6. [pmid: 10449139].
478 Shajahan PM, Glabus MF, Steele JD, Doris AB, Anderson K, Jenkins JA, et al. Left dorso-lateral repetitive transcranial magnetic stimulation affects cortical excitability and functional connectivity, but does not impair cognition in major depression. Progress in Neuro-Psychopharmacology & Biological Psychiatry. Jun. 2002;26(5):945-54. [pmid: 12369271].
479 Shanmugham B, Karp J, Drayer R, Reynolds CF III, Alexopoulos G. Evidence-based pharmacologic interventions for geriatric depression. Psychiatric Clinics of North America. Dec. 2005;28(4):821-35. [pmid: 16325731].
480 Sharma V, Khan M. Identification of bipolar disorder in women with postpartum depression. Bipolar Disorders. 2010;12(3):335-40. [pmid: 20565441].
481 Sharma V, Khan M, Corpse C. Role of lamotrigine in the management of treatment-resistant bipolar II depression: A chart review. Journal of Affective Disorders. 11. 2008;111(1):100-5. [pmid: 18314200].
482 Shields DC, Asaad W, Eskandar EN, Jain FA, Cosgrove GR, Flaherty AW, et al. Prospective assessment of stereotactic ablative surgery for intractable major depression. Biological Psychiatry. 09. 2008;64(6):449-54. [pmid: 18486107].
483 Shteinlukht T. Review of ‘Electroconvulsive therapy: A guide for professionals and their patients’. Psychiatric Services. 2009;60(9).
484 Siddiqui F, Herial NA, Ali II. Cumulative effect of vagus nerve stimulators on intractable seizures observed over a period of 3 years. Epilepsy & Behavior. 2010;18(3):299-302. [pmid: 20580901].
485 Sidhoumi D, Braha S, Bouaziz N, Brunelin J, Benadhira R, Januel D. Evaluation of the therapeutic effect of theta burst stimulation on drug-resistant auditory hallucinations in a schizophrenic patient and its impact on cognitive function and neuronal excitability: A case study. Clinical Neurophysiology. 2010;121(5).
486 Sienaert P, Vansteelandt K, Demyttenaere K, Peuskens J. Randomized comparison of ultra-brief bifrontal and unilateral electroconvulsive therapy for major depression: Clinical efficacy. Journal of Affective Disorders. 2009;116(1-2):106-12. [pmid: 19081638].
487 Simon NM, Connor KM, LeBeau RT, Hoge EA, Worthington JJ III, Zhang W, et al. Quetiapine augmentation of paroxetine CR for the treatment of refractory generalized anxiety disorder: Preliminary findings. Psychopharmacology. 05. 2008;197(4):675-81. [pmid: 18246327].
488 Siwek M, Dudek D, Paul IA, Sowa-Kućma M, Zięba A, Popik P, et al. Zinc supplementation augments efficacy of imipramine in treatment resistant patients: A double blind, placebo-controlled study. Journal of Affective Disorders. 11. 2009;118(1):187-95. [pmid: 19278731].
489 Siwek M, Dudek D, Schlegel-Zawadzka M, Morawska A, Piekoszewski W, Opoka W, et al. Serum zinc level in depressed patients during zinc supplementation of imipramine treatment. Journal of affective disorders. 2010;126(3):447-52. [pmid: 20493532].
490 Sjögren MJ, Hellström PT, Jonsson MA, Runnerstam M, Silander HC, Ben-Menachem E. Cognition-enhancing effect of vagus nerve stimulation in patients with Alzheimer's disease: A pilot study. Journal of Clinical Psychiatry. Nov. 2002;63(11):972-80. [pmid: 12444809].
491 Smith DF, Stork BS, Wegener G, Ashkanian M, Jakobsen S, Bender D, et al. [^11^C]mirtazapine binding in depressed antidepressant nonresponders studied by PET neuroimaging. Psychopharmacology. 2009;206(1):133-40. [pmid: 19536526].
492 Sobiś J, Jarząb M, Hese RT, Sieroń A, Zyss T, Gorczyca P, et al. Therapeutic efficacy assessment of weak variable magnetic fields with low value of induction in patients with drug-resistant depression. Journal of Affective Disorders. 2010;123(1-3):321-6. [pmid: 19896204].
493 Solyom L, Solyom C, Ledwidge B. Fluoxetine in panic disorder. The Canadian Journal of Psychiatry. La Revue canadienne de psychiatrie. 06. 1991;36(5):378-80.
494 Sommer M, Dieterich A, Rüther E, Paulus W, Wiltfang J. Increased transcranial magnetic motor threshold after ECT: a case report. European Archives of Psychiatry and Clinical Neuroscience. 2002;252(5):250-2. [pmid: 12451468].
495 Sonino N, Navarrini C, Ruini C, Ottolini F, Paoletta A, Fallo F, et al. Persistent psychological distress in patients treated for endocrine disease. Psychotherapy and Psychosomatics. Mar-Apr. 2004;73(2):78-83. [pmid: 14767149].
496 Sookman D, Pinard G. Integrative cognitive therapy for obsessive-compulsive disorder: a focus on multiple schemas. Cognitive and Behavioral Practice. Fal. 1999;6(4):351-62.
497 Sovner R. Amphetamine and tranylcypromine in treatment-resistant depression. Biological Psychiatry. 12. 1990;28(11):1011-2. [pmid: 2275949].
498 Speer AM, Benson BE, Kimbrell TK, Wassermann EM, Willis MW, Herscovitch P, et al. Opposite effects of high and low frequency rTMS on mood in depressed patients: Relationship to baseline cerebral activity on PET. Journal of Affective Disorders. 2009;115(3):386-94. [pmid: 19027962].
499 Speer AM, Kimbrell TA, Wasermann EM, Repella JD, Willis MW, Herscovitch P, et al. Opposite effects of high and low frequency rTMS on regional brain activity in depressed patients. Biological Psychiatry. Dec. 2000;48(12):1133-41. [pmid: 11137053].
500 Sperling W, Reulbach U, C M, Kornhuber J, Bleich S. Vagus nerve stimulation in a patient with Gilles de la Tourette syndrome and major depression. Pharmacopsychiatry. May. 2008;41(3):117-8. [pmid: 18484555].
501 Sperry L. Effective couples therapy and psych 101: you can't have one without the other. American Journal of Family Therapy. Jul-Sep. 2004;32(4):325-35.
502 Spirito A, Abebe KZ, Iyengar S, Brent D, Vitiello B, Clarke G, et al. Sources of site differences in the efficacy of a multisite clinical trial: The treatment of SSRI-resistant depression in adolescents. Journal of Consulting and Clinical Psychology. Jun. 2009;77(3):439-50. [pmid: 19485586].
503 Staller JA. Chronic complex depression. Psychiatric Services. Jun. 2003;54(6):771. [pmid: 12773588].
504 Stålsett G, Engedal LG, Austad A. The persecuting God and the crucified self: The case of Olav and the transformation of his pathological self-image. Pragmatic Case Studies in Psychotherapy. 2010;6(2):49-133.
505 Stamm TJ, Adli M, Kirchheiner J, Smolka MN, Kaiser R, Tremblay PB, et al. Serotonin transporter gene and response to lithium augmentation in depression. Psychiatric Genetics. 04. 2008;18(2):92-7. [pmid: 18349701].
506 Steele JD, Glabus MF, Shajahan PM, Ebmeier KP. Increased cortical inhibition in depression: a prolonged silent period with transcranial magnetic stimulation (TMS). Psychological Medicine. May. 2000;30(3):565-70. [pmid: 10883712].
507 Stefan K, Wycislo M, Gentner R, Schramm A, Naumann M, Reiners K, et al. Temporary occlusion of associative motor cortical plasticity by prior dynamic motor training. Cerebral Cortex. Mar. 2006;16(3):376-85. [pmid: 15930370].
508 Stewart JW, McGrath PJ, Deliyannides DA, Quitkin FM. Does dual antidepressant therapy as initial treatment hasten and increase remission from depression?. Journal of Psychiatric Practice. 2009;15(5):337-45. [pmid: 19820552].
509 Suarez RO, Golby A, Whalen S, Sato S, Theodore WH, Kufta CV, et al. Contributions to singing ability by the posterior portion of the superior temporal gyrus of the non-language-dominant hemisphere: First evidence from subdural cortical stimulation, WADA testing, and fMRI. Cortex: A Journal Devoted to the Study of the Nervous System and Behavior. 2010;46(3):343-53. [pmid: 19570530].
510 Subramanian P, Burhan A. Worsening of “passivity” symptoms with low-frequency bilateral temporo-parietal repetitive transcranial magnetic stimulation used to treat refractory auditory hallucinations: A case report. Schizophrenia Research. 2010;116(2-3):291-2. [pmid: 19926454].
511 Sussman N. Anxiolytic antidepressant augmentation. Journal of Clinical Psychiatry. 1998;59(5):42-50. [pmid: 9635547].
512 Sutherland EM, Oliver JE, Knight DR. E E G, memory and confusion in dominant, non-dominant and bi-temporal E C T. British Journal of Psychiatry. 1969;115(526):1059-64. [pmid: 5386995].
513 Svensson P, Miles TS, McKay D, Ridding MC. Suppression of motor evoked potentials in a hand muscle following prolonged painful stimulation. European Journal of Pain. Feb. 2003;7(1):55-62. [pmid: 12527318].
514 Taylor FB, Prather MR. The efficacy of nefazodone augmentation for treatment-resistant depression with anxiety symptoms or anxiety disorder. Depression and Anxiety. 2003;18(2):83-8. [pmid: 12964175].
515 Teodor Hese R, Jedrzejewska B. Multiple EEG examinations in patients with recurrent, refractory major depression and bipolar depression after course of UECT. Archives of Psychiatry and Psychotherapy. Sep. 2000;2(3):17-24.
516 Terney D, Chaieb L, Moliadze V, Antal A, Paulus W. Increasing human brain excitability by transcranial high- frequency random noise stimulation. Journal of Neuroscience. Dec. 2008;28(52):14147-55. [pmid: 19109497].
517 Thase ME, Feighner JP, Lydiard RB. Citalopram treatment of fluoxetine nonresponders. Journal of Clinical Psychiatry. 09. 2001;62(9):683-7. [pmid: 11681763].
518 Thase ME, Reynolds CF, Frank E, Simons AD, et al. Response to cognitive-behavioral therapy in chronic depression. Journal of Psychotherapy Practice & Research. Sum. 1994;3(3):204-14.
519 Thirthalli J, Kumar CN, Bangalore RP, Gangadhar BN. Speed of response to threshold and suprathreshold bilateral ECT in depression, mania and schizophrenia. Journal of Affective Disorders. 2009;117(1-2):104-7. [pmid: 19157566].
520 Tkachuk GA. Controlled trial of a multicomponent cognitive-behavioral group treatment for irritable bowel syndrome. Dissertation Abstracts International: Section B: The Sciences and Engineering. Apr. 2002;62(10):4807.
521 Tracy DK, O'Daly O, Joyce DW, Michalopoulou PG, Basit BB, Dhillon G, et al. An evoked auditory response fMRI study of the effects of rTMS on putative AVH pathways in healthy volunteers. Neuropsychologia. 2010;48(1):270-7. [pmid: 19769994].
522 Triggs WJ, McCoy KJM, Greer R, Rossi F, Bowers D, Kortenkamp S, et al. Effects of left frontal transcranial magnetic stimulation on depressed mood, cognition, and corticomotor threshold. Biological Psychiatry. Jun. 1999;45(11):1440-6. [pmid: 10356626].
523 Tsai HC, Chen SY, Tsai ST, Hung HY, Chang CH. Hypomania following bilateral ventral capsule stimulation in a patient with refractory obsessive-compulsive disorder. Biological Psychiatry. 2010;68(2):e7-e8. [pmid: 20553748].
524 Turner RM. The Cognitive-Behavior Therapy Case Conference. Cognitive and Behavioral Practice. 1998;5(2):297-307.
525 Tutty S, Ludman EJ, Simon G. Feasibility and acceptability of a telephone psychotherapy program for depressed adults treated in primary care. General Hospital Psychiatry. Nov-Dec. 2005;27(6):400-10. [pmid: 16271654].
526 Ueda S, Koyama K, Okubo Y. Marked improvement of psychotic symptoms after electroconvulsive therapy in Parkinson disease. The Journal of ECT. 2010;26(2):111-5. [pmid: 20386461].
527 Valevski A, Pickholtz E, Roz N, Weizman A, Rehavi M. Lack of modulatory effect of short-term repeated electroconvulsive therapy on platelet vesicular monoamine transporter 2 (VMAT2) in depressed patients. Journal of Neural Transmission. 2010;117(7):881-5. [pmid: 20544232].
528 Valldeoriola F, Regidor I, Mínguez-Castellanos A, Lezcano E, García-Ruiz P, Rojo A, et al. Efficacy and safety of pallidal stimulation in primary dystonia: Results of the Spanish multicentric study. Journal of Neurology, Neurosurgery & Psychiatry. 2010;81(1):65-9.
529 van Amelsvoort T. Serious hypertensive reaction after switching from clomipramine to moclobemide. Irish Journal of Psychological Medicine. Jun. 1998;15(2):77-8.
530 Van Ameringen M, Mancini C, Patterson B, Bennett M. Topiramate augmentation in treatment-resistant obsessive-compulsive disorder: A retrospective, open-label case series. Depression and Anxiety. 2006;23(1):1-5. [pmid: 16178009].
531 van der Wurff FB, Stek ML, Hoogendijk WJG, Beekman ATF. Discrepancy Between Opinion and Attitude on the Practice of ECT by Psychiatrists Specializing in Old Age in the Netherlands. The Journal of ECT. 2004;20(1):37-41. [pmid: 15087995].
532 van Honk J, Schutter DJLG, Putman P, de Haan EHF, d'Alfonso AAL. Reductions in phenomenological, physiological and attentional indices of depressive mood after 2 Hz rTMS over the right parietal cortex in healthy human subjects. Psychiatry Research. Aug. 2003;120(1):95-101. [pmid: 14500118].
533 Vedel E, Emmelkamp PMG. Behavioral couple therapy in the treatment of a female alcohol-dependent patient with comorbid depression, anxiety, and personality disorders. Clinical Case Studies. Jul. 2004;3(3):187-205.
534 Vedeniapin A, Cheng L, George MS. Feasibility of simultaneous cognitive behavioral therapy and left prefrontal rTMS for treatment resistant depression. Brain Stimulation. 2010;3(4):207-10. [pmid: 20965449].
535 Velasco M, Velasco F, Jiménez F, Carrillo-Ruiz JD, Velasco AL, Sal1n-Pascual R. Electrocortical and behavioral responses elicited by acute electrical stimulation of inferior thalamic peduncle and nucleus reticularis thalami in a patient with major depression disorder. Clinical Neurophysiology. Feb. 2006;117(2):320-7. [pmid: 16403484].
536 Vercammen A, Knegtering H, Bruggeman R, Westenbroek HM, Jenner JA, Slooff CJ, et al. Effects of bilateral repetitive transcranial magnetic stimulation on treatment resistant auditory–verbal hallucinations in schizophrenia: A randomized controlled trial. Schizophrenia Research. 2009;114(1-3):172-9. [pmid: 19679450].
537 Vercammen A, Knegtering H, Liemburg EJ, den Boer JA, Aleman A. Functional connectivity of the temporo-parietal region in schizophrenia: Effects of rtms treatment of auditory hallucinations. Journal of Psychiatric Research. 2010;44(11):725-31. [pmid: 20189190].
538 Verhoeven W, Tuinier S, Egger J, van Erp F, Tuerlings J. Avolition in a patient with hypogonadism. European Journal of Psychiatry. 10. 2008;22(4):195-9.
539 Vinar O, Vinarova E. Tianeptine helps depressed patients resistant to serotonin function enhancing drugs. Homeostasis in Health and Disease. 09. 1997;38(4):170-2.
540 Vulink NCC, Denys D, Fluitman SBAHA, Meinardi JCM, Westenberg HGM. Quetiapine augments the effect of citalopram in non-refractory obsessive-compulsive disorder: A randomized, double-blind, placebo-controlled study of 76 patients. Journal of Clinical Psychiatry. 2009;70(7):1001-8. [pmid: 19497245].
541 Wachtel LE, Griffin M, Reti IM. Electroconvulsive therapy in a man with autism experiencing severe depression, catatonia, and self-injury. The Journal of ECT. 2010;26(1):70-3. [pmid: 19483640].
542 Wada T, Kanno M, Aoshima T, Otani K. Dose-dependent augmentation effect of bromocriptine in a case with refractory depression. Progress in Neuro-Psychopharmacology & Biological Psychiatry. 02. 2001;25(2):457-62. [pmid: 11294489].
543 Wagner KD. Major depression in children and adolescents. Psychiatric Annals. Apr. 2003;33(4):266-70.
544 Walter G, Tormos JM, Israel JA, Pascual-Leone A. Trascranial magnetic stimulation in young persons: A review of known cases. Journal of Child and Adolescent Psychopharmacology. Spr. 2001;11(1):69-75. [pmid: 11322748].
545 Wang H, Chen X, Lin Z, Shao Z, Sun B, Shen H, et al. Long-term effect of vagus nerve stimulation on interictal epileptiform discharges in refractory epilepsy. Journal of the Neurological Sciences. 2009;284(1-2):96-102. [pmid: 19427651].
546 Warnell RL, Elahi N. Introduction of vagus nerve stimulation into a maintenance electroconvulsive therapy regimen: A case study and cost analysis. Journal of ECT. Jun. 2007;23(2):114-9. [pmid: 17548984].
547 Wasserman EM, Greenberg BD, Nguyen MB, Murphy DL. Motor cortex excitability correlates with an anxiety-related personality trait. Biological Psychiatry. Sep. 2001;50(5):377-82. [pmid: 11543742].
548 Watts BV, Groft A. Retrospective evaluation of the dexamethasone suppression test as a predictor of response to electroconvulsive therapy in patients with comorbid major depressive disorder and posttraumatic stress disorder. The Journal of ECT. 2010;26(3):213-7. [pmid: 20386115].
549 Weise D, Schramm A, Stefan K, Wolters A, Reiners K, Naumann M, et al. The two sides of associative plasticity in writer's cramp. Brain: A Journal of Neurology. Oct. 2006;129(10):2709-21. [pmid: 16921180].
550 Westra HA. Managing resistance in cognitive behavioural therapy: the application of motivational interviewing in mixed anxiety and depression. Cognitive Behaviour Therapy. 2004;33(4):161-75. [pmid: 15625790].
551 Wilz G, Barskova T. Evaluation of a cognitive behavioral group intervention program for spouses of stroke patients. Behaviour Research and Therapy. Oct. 2007;45(10):2508-17. [pmid: 17555707].
552 Wolters A, Sandbrink F, Schlottmann A, Kunesch E, Stefan K, Cohen LG, et al. A temporally asymmetric hebbian rule governing plasticity in the human motor cortex. Journal of Neurophysiology. May. 2003;89(5):2339-45. [pmid: 12612033].
553 Worthington JJ III, Kinrys G, Wygant LE, Pollack MH. Aripiprazole as an augmentor of selective serotonin reuptake inhibitors in depression and anxiety disorder patients. International Clinical Psychopharmacology. 01. 2005;20(1):9-11. [pmid: 15602109].
554 Wright JH. A 25-year-old man with chronic severe depression. Psychiatric Annals. Sep. 2003;33(9):552-4.
555 Wright JH. Cognitive behavior therapy for chronic depression: combined treatment may succeed when pharmacologic monotherapy fails. Psychiatric Annals. Dec. 2003;33(12):777-84.
556 Wu WH, Huo SJ, Chih-Ya C, Chen-Jee H, Tsai SJ. Association study of the 5-HT(6) receptor polymorphism (C267T) and symptomatology and antidepressant response in major depressive disorders. Neuropsychobiology. 11. 2001;44(4):172-5. [pmid: 11702016].
557 Yatham LN, Liddle PF, Lam RW, Zis AP, Stoessl AJ, Sossi V, et al. Effect of electroconvulsive therapy on brain 5-HT_2_ receptors in major depression. British Journal of Psychiatry. 2010;196(6):474-9. [pmid: 20513859].
558 Yeh YW, Chen CH, Kuo SC, Wang SC, Chen CK, Feng HM. High-dose duloxetine for treatment-resistant obsessive-compulsive disorder: A case report with sustained full remission. Clinical neuropharmacology. 2009;32(3):174-6. [pmid: 19483491].
559 Yoshida K, Sugawara Y, Higuchi H. Dramatic Remission of Treatment-resistant Depression after the Cessation of Tricyclic Antidepressants: A Case Report. Pharmacopsychiatry. 05. 2006;39(3):114. [pmid: 16721702].
560 Yoshimi A, Togo T, Sugiyama N, Uehara K, Otsuka T, Karashima A, et al. Treatment of refractory tardive dyskinesia with donepezil in an elderly patient with depression. Psychogeriatrics. 2008;8(4):196-8.
561 Zahodne LB, Okun MS, Foote KD, Fernandez HH, Rodriguez RL, Kirsch-Darrow L, et al. Cognitive declines one year after unilateral deep brain stimulation surgery in Parkinson's disease: A controlled study using reliable change. The Clinical Neuropsychologist. 2009;23(3):385-405. [pmid: 18821180].
562 Zarate CA Jr, Payne JL, Quiroz J, Sporn J, Denicoff KK, Luckenbaugh D, et al. An Open-Label Trial of Riluzole in Patients With Treatment-Resistant Major Depression. The American Journal of Psychiatry. 01. 2004;161(1):171-4. [pmid: 14702270].
563 Zhang TJ, Wu QZ, Huang XQ, Sun XL, Zou K, Lui S, et al. Magnetization transfer imaging reveals the brain deficit in patients with treatment-refractory depression. Journal of Affective Disorders. 2009;117(3):157-61. [pmid: 19211150].
564 Zhang X, Zhang Z, Sha W, Xie C, Xi G, Zhou H, et al. Electroconvulsive therapy increases glial cell-line derived neurotrophic factor (GDNF) serum levels in patients with drug-resistant depression. Psychiatry Research. 2009;170(2-3):273-5. [pmid: 19896212].
565 Zheng XM. Regional cerebral blood flow changes in drug-resistant depressed patients following treatment with transcranial magnetic stimulation: A statistical parametric mapping analysis. Psychiatry Research: Neuroimaging. Dec. 2000;100(2):75-80.
566 Ziemann U, Iliac TV, Pauli C, Meintzschel F, Ruge D. Learning modifies subsequent induction of long-term potentiation-like and long-term depression-like plasticity in human motor cortex. Journal of Neuroscience. Feb. 2004;24(7):1666-72. [pmid: 14973238].
567 Zisook S, Chentsova-Dutton YE, Smith-Vaniz A, Kline NA, Ellenor GL, Kodsi AB, et al. Nefazodone in patients with treatment-refractory posttraumatic stress disorder. Journal of Clinical Psychiatry. 03. 2000;61(3):203-8. [pmid: 10817106].
568 Zöger S, Erlandsson S, Svedlund J, Holgers KM. Benefits from group psychotherapy in the treatment of severe refractory tinnitus. Audiological Medicine. 2008;6(1):62-72.
569 Zwanzger P, Baghai TC, Padberg F, Ella R, Minov C, Mikhaiel P, et al. The combined dexamethasone-CRH test before and after repetitive transcranial magnetic stimulation (rTMS) in major depression. Psychoneuroendocrinology. Apr. 2003;28(3):376-85. [pmid: 12573303].
570 Zwanzger P, Ella R, Keck ME, Rupprecht R, Padberg F. Occurrence of delusions during repetitive transcranial magnetic stimulation (rTMS) in major depression. Biological Psychiatry. Apr. 2002;51(7):602-3. [pmid: 11950462].
571 Zwanzger P, Eser D, Völkel N, Baghai TC, Möller HJ, Rupprecht R, et al. Effects of repetitive transcranial magnetic stimulation (rTMS) on panic attacks induced by cholecystokinin-tetrapeptide (CCK-4). International Journal of Neuropsychopharmacology. Apr. 2007;10(2):285-9. [pmid: 16817979].
572 Berman RM, Narasimhan M, Sanacora G, Miano AP, Hoffman RE, Hu XS, et al. A randomized clinical trial of repetitive transcranial magnetic stimulation in the treatment of major depression. Biological Psychiatry. Feb. 2000;47(4):332-7. [pmid: 10686268].
573 Boutros NN, Gueorguieva R, Hoffman RE, Oren DA, Feingold A, Berman RM. Lack of a therapeutic effect of a 2-week sub-threshold transcranial magnetic stimulation course for treatment-resistant depression. Psychiatry Research. Dec. 2002;113(3):245-54. [pmid: 12559481].
574 Fang Y, Yuan C, Xu Y, Chen J, Wu Z, Cao L, et al. Comparisons of the efficacy and tolerability of extended-release venlafaxine, mirtazapine, and paroxetine in treatment-resistant depression: A double-blind, randomized pilot study in a Chinese population, Journal of Clinical Psychopharmacology. US. Lippincott Williams & Wilkins. 2010:357-64.
575 Garcia-Toro M, Mayol A, Arnillas H, Capllonch I, Ibarra O, Crespí M, et al. Modest adjunctive benefit with transcranial magnetic stimulation in medication-resistant depression. Journal of Affective Disorders. May. 2001;64(2):271-5. [pmid: 11313095].
576 Knapp M, Romeo R, Mogg A, Eranti S, Pluck G, Purvis R, et al. Cost-effectiveness of transcranial magnetic stimulation vs electroconvulsive therapy for severe depression: A multi-centre randomised controlled trial. Journal of Affective Disorders. 2008:273-85.
577 Kocsis JH, Gelenberg AJ, Rothbaum BO, Klein DN, Trivedi MH, Manber R, et al. Cognitive behavioral analysis system of psychotherapy and brief supportive psychotherapy for augmentation of antidepressant nonresponse in chronic depression: The REVAMP trial, Archives of General Psychiatry. US. American Medical Assn. 2009:1178-88.
578 Manes F, Jorge R, Morcuende M, Yamada T, Paradiso S, Robinson RG. A controlled study of repetitive transcranial magnetic stimulation as a treatment of depression in the elderly. International Psychogeriatrics. Jun. 2001;13(2):225-31. [pmid: 11495396].
579 Möller AL, Hjaltason Ó, Ívarsson Ó, Stefánsson SB. The effects of repetitive transcranial magnetic stimulation on depressive symptoms and the P-sub-3-sub-0-sub-0 event-related potential. Nordic Journal of Psychiatry. 2006;60(4):282-5. [pmid: 16923636].
580 Moore RG, Blackburn IM. Cognitive therapy in the treatment of non-responders to antidepressant medication: A controlled pilot study. Behavioural and Cognitive Psychotherapy. 1997;25(3):251-9.
581 Moser DJ, Jorge RE, Manes F, Paradiso S, Benjamin ML, Robinson RG. Improved executive functioning following repetitive transcranial magnetic stimulation. Neurology. 2002:1288-90.
582 Nierenberg AA, Papakostas GI, Petersen T, Montoya HD, Worthington JJ, Tedlow J, et al. Lithium augmentation of nortriptyline for subjects resistant to multiple antidepressants, Journal of Clinical Psychopharmacology. US. Lippincott Williams & Wilkins. 2003:92-5.
583 Su TP, Huang CC, Wei IH. Add-On rTMS for medication-resistant depression: a randomized, double-blind, sham-controlled trial in Chinese patients. Journal of Clinical Psychiatry. Jul. 2005;66(7):930-7. [pmid: 16013911].
584 Wiles NJ, Hollinghurst S, Mason V, Musa M, Burt V, Hyde J, et al. A randomized controlled trial of cognitive behavioural therapy as an adjunct to pharmacotherapy in primary care based patients with treatment resistant depression: A pilot study. Behavioural and Cognitive Psychotherapy. Jan. 2008;36(1):21-33.
585 Zheng H, Zhang L, Li L, Liu P, Gao J, Liu X, et al. High-frequency rTMS treatment increases left prefrontal myo-inositol in young patients with treatment-resistant depression, Progress in Neuro-Psychopharmacology & Biological Psychiatry. Netherlands. Elsevier Science. 2010:1189-95.
586 Kauffmann CD, Cheema MA, Miller BE. Slow right prefrontal transcranial magnetic stimulation as a treatment for medication-resistant depression: a double-blind, placebo-controlled study. Depression and Anxiety. 2004;19(1):59-62. [pmid: 14978787].
587 Janicak PG, Nahas Z, Lisanby SH, Solvason HB, Sampson SM, McDonald WM, et al. Durability of clinical benefit with transcranial magnetic stimulation (TMS) in the treatment of pharmacoresistant major depression: Assessment of relapse during a 6-month, multisite, open-label study, Brain Stimulation. Netherlands. Elsevier Science. 2010:187-99.
588 Rush AJ, Marangell LB, Sackeim HA, George MS, Brannan SK, Davis SM, et al. Vagus nerve stimulation for treatment-resistant depression: a randomized, controlled acute phase trial. Biological Psychiatry. Sep. 2005;58(5):347-54. [pmid: 16139580].
589 Thase ME, Corya SA, Osuntokun O, Case M, Henley DB, Sanger TM, et al. A randomized, double-blind comparison of olanzapine/fluoxetine combination, olanzapine, and fluoxetine in treatment-resistant major depressive disorder, Journal of Clinical Psychiatry. US. Physicians Postgraduate Press. 2007:224-36.

## PubMed = 1,384 articles (excluding duplicates)

1 Recognize the subtleties of depression in primary care. Dis Manag Advis. Feb. 2002;8(2):28-32. 17. [pmid: 11910958].
2 Vagus nerve stimulation for treatment-resistance depression. Technol Eval Cent Asses Program Exec Summ. Aug. 2005;20(8):1-2.
3 Drug treatments for bipolar disorder: 1--Acute manic or depressive episodes. Drug Ther Bull. Apr. 2005;43(4):28-32. [pmid: 15849974].
4 Magnetic stimulation as therapy. Unlocking depression, chronic pain and more. Mayo Clin Health Lett. Dec. 2009;27(12):1-3.
5 Transcranial magnetic stimulation for depression. Technol Eval Cent Asses Program Exec Summ. Oct. 2009;24(5):1-3.
6 Easing the burden of treatment-resistant depression. J Clin Psychiatry. Feb. 2009;70(2):273-80. [pmid: 19265643].
7 Options for treatment-resistant depression. Why electroconvulsive therapy may be the best alternative to medication. Harv Ment Health Lett. Jan. 2009;25(7):1-3.
8 Transcranial magnetic stimulation. Research helps clarify who is likely to benefit from this treatment. Harv Ment Health Lett. Sep. 2010;27(3):6.
9 Abbass AA. Intensiveshort-term dynamic psychotherapy of treatment-resistant depression: a pilot study. Depress Anxiety. 2006;23(7):449-52. [pmid: 16845654].
10 Ables AZ, Baughman OL 3rd. Antidepressants: update on new agents and indications. Am Fam Physician. Feb. 1. 2003;67(3):547-54. [pmid: 12588077].
11 Abou-Saleh MT, Anderson DN, Collins J, Hughes K, Cattell RJ, Hamon CG, et al. The role of pterins in depression and the effects of antidepressive therapy. Biol Psychiatry. Oct. 1. 1995;38(7):458-63. [pmid: 8672606].
12 Abraham G, Milev R, Stuart Lawson J. T3 augmentation of SSRI resistant depression. J Affect Disord. Apr. 2006;91(2-3):211-5. [pmid: 16483669].
13 Abrams R. Is unilateral electroconvulsive therapy really the treatment of choice in endogenous depression?. Ann N Y Acad Sci. 1986;462:50-5. [pmid: 3518574].
14 Abrams R, Swartz CM, Vedak C. Antidepressant effects of right versus left unilateral ECT and the lateralization theory of ECT action. Am J Psychiatry. Sep. 1989;146(9):1190-2. [pmid: 2669536].
15 Abrams R, Swartz CM, Vedak C. Antidepressant effects of high-dose right unilateral electroconvulsive therapy. Arch Gen Psychiatry. Aug. 1991;48(8):746-8. [pmid: 1883258].
16 Abrams R, Volavka J, Schrift M. Brief pulse ECT in melancholia. EEG and clinical effects. J Nerv Ment Dis. Jan. 1992;180(1):55-7. [pmid: 1538208].
17 Ackerman DL, Unutzer J, Greenland S, Gitlin M. Inpatient treatment of depression and associated hospital charges. Pharmacoepidemiol Drug Saf. Apr-May. 2002;11(3):219-27. [pmid: 12051121].
18 Adlersberg S, Toren P, Mester R, Rehavi M, Skolnick P, Weizman A. Verapamil is not an antidepressant in patients resistant to tricyclic antidepressants. Clin Neuropharmacol. Jun. 1994;17(3):294-7. [pmid: 9316675].
19 Adli M, Baethge C, Heinz A, Langlitz N, Bauer M. Is dose escalation of antidepressants a rational strategy after a medium-dose treatment has failed? A systematic review. Eur Arch Psychiatry Clin Neurosci. Dec. 2005;255(6):387-400. [pmid: 15868067].
20 Adli M, Berghofer A, Linden M, Helmchen H, Muller-Oerlinghausen B, Mackert A, et al. Effectiveness and feasibility of a standardized stepwise drug treatment regimen algorithm for inpatients with depressive disorders: results of a 2-year observational algorithm study. J Clin Psychiatry. Sep. 2002;63(9):782-90. [pmid: 12363118].
21 Adli M, Hollinde DL, Stamm T, Wiethoff K, Tsahuridu M, Kirchheiner J, et al. Response to lithium augmentation in depression is associated with the glycogen synthase kinase 3-beta -50T/C single nucleotide polymorphism. Biol Psychiatry. Dec. 1. 2007;62(11):1295-302. [pmid: 17628506].
22 Adli M, Pilhatsch M, Bauer M, Koberle U, Ricken R, Janssen G, et al. Safety of high-intensity treatment with the irreversible monoamine oxidase inhibitor tranylcypromine in patients with treatment-resistant depression. Pharmacopsychiatry. Nov. 2008;41(6):252-7. [pmid: 19067263].
23 Adli M, Rush AJ, Moller HJ, Bauer M. Algorithms for optimizing the treatment of depression: making the right decision at the right time. Pharmacopsychiatry. Nov. 3. 2003;36:S222-9. [pmid: 14677083].
24 Agelink MW, Andrich J, Postert T, Wurzinger U, Zeit T, Klotz P, et al. Relation between electroconvulsive therapy, cognitive side effects, neuron specific enolase, and protein S-100. J Neurol Neurosurg Psychiatry. Sep. 2001;71(3):394-6. [pmid: 11511718].
25 Agius M, Gardner J, Liu K, Zaman R. An audit to compare discharge rates between antidepressant monotherapies prescribed for pure unipolar depression versus depression in the presence of other indications. Psychiatr Danub. Jun. 2010;22(2):346-9. [pmid: 20562779].
26 Aguera LF, Rojo JE, Ros S, de la Gandara J, de Pedro JM. Antidepressant combinations: epidemiological considerations. Acta Psychiatr Scand Suppl. 2005;(428):7-10. 36. [pmid: 16307614].
27 Ahdab R, Ayache SS, Brugieres P, Goujon C, Lefaucheur JP. Comparison of “standard” and “navigated” procedures of TMS coil positioning over motor, premotor and prefrontal targets in patients with chronic pain and depression. Neurophysiol Clin. Mar. 2010;40(1):27-36. [pmid: 20230933].
28 Ahmed SH, Zaheeruddin. Early experience with fluoxetine. J Pak Med Assoc. Nov. 1991;41(11):275-7. [pmid: 1766070].
29 Akiskal HS. A proposed clinical approach to chronic and “resistant” depressions: evaluation and treatment. J Clin Psychiatry. Oct. 1985;46(10 Pt 2):32-7. [pmid: 3930475].
30 Akiskal HS. Approach to chronic and treatment-resistant depressions. Adv Biochem Psychopharmacol. 1985;40:159-63. [pmid: 4025035].
31 Alao AO, Malhotra K, Pies R, Dewan MJ. Pharmacological strategies in treatment-resistant depression. West Afr J Med. Sep. 2003;22(3):211-8. [pmid: 14696943].
32 Albers LJ, Reist C, Helmeste D, Vu R, Tang SW. Paroxetine shifts imipramine metabolism. Psychiatry Res. Jan. 31. 1996;59(3):189-96. [pmid: 8930024].
33 Alexopoulos GS, Canuso CM, Gharabawi GM, Bossie CA, Greenspan A, Turkoz I, et al. Placebo-controlled study of relapse prevention with risperidone augmentation in older patients with resistant depression. Am J Geriatr Psychiatry. Jan. 2008;16(1):21-30. [pmid: 17928573].
34 Alpert JE, Papakostas G, Mischoulon D, Worthington JJ 3rd, Petersen T, Mahal Y, et al. S-adenosyl-L-methionine (SAMe) as an adjunct for resistant major depressive disorder: an open trial following partial or nonresponse to selective serotonin reuptake inhibitors or venlafaxine. J Clin Psychopharmacol. Dec. 2004;24(6):661-4. [pmid: 15538131].
35 Altamura AC, Dell'Osso B, Buoli M, Bosi M, Mundo E. Short-term intravenous citalopram augmentation in partial/nonresponders with major depression: a randomized placebo-controlled study. Int Clin Psychopharmacol. Jul. 2008;23(4):198-202. [pmid: 18545057].
36 Altamura AC, Dell'Osso B, Buoli M, Zanoni S, Mundo E. Intravenous augmentative citalopram versus clomipramine in partial/nonresponder depressed patients: a short-term, low dose, randomized, placebo-controlled study. J Clin Psychopharmacol. Aug. 2008;28(4):406-10. [pmid: 18626267].
37 Amiaz R, Stein O, Schreiber S, Danon PN, Dolberg OT, Grunhaus L. Magnetic and seizure thresholds before and after six electroconvulsive treatments. J Ect. Sep. 2001;17(3):195-7. [pmid: 11528311].
38 Amital D, Fostick L, Silberman A, Beckman M, Spivak B. Serious life events among resistant and non-resistant MDD patients. J Affect Disord. Oct. 2008;110(3):260-4. [pmid: 18262654].
39 Amsterdam JD, Berwish N. Treatment of refractory depression with combination reserpine and tricyclic antidepressant therapy. J Clin Psychopharmacol. Aug. 1987;7(4):238-42. [pmid: 3305592].
40 Amsterdam JD, Berwish NJ. High dose tranylcypromine therapy for refractory depression. Pharmacopsychiatry. Jan. 1989;22(1):21-5. [pmid: 2710808].
41 Amsterdam JD, Garcia-Espana F, Rosenzweig M. Clomipramine augmentation in treatment-resistant depression. Depress Anxiety. 1997;5(2):84-90. [pmid: 9262938].
42 Amsterdam JD, Hornig-Rohan M. Treatment algorithms in treatment-resistant depression. Psychiatr Clin North Am. Jun. 1996;19(2):371-86. [pmid: 8827195].
43 Amsterdam JD, Maislin G, Potter L. Fluoxetine efficacy in treatment resistant depression. Prog Neuropsychopharmacol Biol Psychiatry. Mar. 1994;18(2):243-61. [pmid: 8208976].
44 Amsterdam JD, Shults J. MAOI efficacy and safety in advanced stage treatment-resistant depression--a retrospective study. J Affect Disord. Dec. 2005;89(1-3):183-8. [pmid: 16213594].
45 Ananth J. Treatment-resistant depression. Psychother Psychosom. 1998;67(2):61-70. [pmid: 9556196].
46 Anderson DN, Wilkinson AM, Abou-Saleh MT, Blair JA. Recovery from depression after electroconvulsive therapy is accompanied by evidence of increased tetrahydrobiopterin-dependent hydroxylation. Acta Psychiatr Scand. Jul. 1994;90(1):10-3. [pmid: 7976441].
47 Anderson IM, Delvai NA, Ashim B, Ashim S, Lewin C, Singh V, et al. Adjunctive fast repetitive transcranial magnetic stimulation in depression. Br J Psychiatry. Jun. 2007;190:533-4. [pmid: 17541116].
48 Andrews JM, Nemeroff CB. Contemporary management of depression. Am J Med. Dec. 19. 1994;97(6A):24S-32S. [pmid: 7992823].
49 Andrews JM, Ninan PT, Nemeroff CB. Venlafaxine: a novel antidepressant that has a dual mechanism of action. Depression. 1996;4(2):48-56. [pmid: 9160640].
50 Antai-Otong D. The art of prescribing. Monotherapy antidepressant: a thing of the past? Implications for the treatment of major depressive disorder. Perspect Psychiatr Care. Jul. 2007;43(3):142-5. [pmid: 17576307].
51 Antonuccio DO, Akins WT, Chatham PM, Monagin JA, Tearnan BH, Ziegler BL. An exploratory study: the psychoeducational group treatment of drug-refractory unipolar depression. J Behav Ther Exp Psychiatry. Dec. 1984;15(4):309-13. [pmid: 6396319].
52 Anttila S, Huuhka K, Huuhka M, Rontu R, Hurme M, Leinonen E, et al. Interaction between 5-HT1A and BDNF genotypes increases the risk of treatment-resistant depression. J Neural Transm. 2007;114(8):1065-8. [pmid: 17401528].
53 Antunes PB, Fleck MP. Clinical outcomes and quality of life in patients submitted to electroconvulsive therapy. J ECT. Sep. 2009;25(3):182-5. [pmid: 19455062].
54 Aoyama Y, Hanaoka N, Kameyama M, Suda M, Sato T, Song M, et al. Stimulus intensity dependence of cerebral blood volume changes in left frontal lobe by low-frequency rTMS to right frontal lobe: A near-infrared spectroscopy study. Neurosci Res. Jan. 2009;63(1):47-51. [pmid: 18992287].
55 Appelberg BG, Syvalahti EK, Koskinen TE, Mehtonen OP, Muhonen TT, Naukkarinen HH. Patients with severe depression may benefit from buspirone augmentation of selective serotonin reuptake inhibitors: results from a placebo-controlled, randomized, double-blind, placebo wash-in study. J Clin Psychiatry. Jun. 2001;62(6):448-52. [pmid: 11465522].
56 Arean PA, Alvidrez J. Treating depressive disorders: who responds, who does not respond, and who do we need to study?. J Fam Pract. Jun. 2001;50(6):E2. [pmid: 11401752].
57 Armitage R, Husain M, Hoffmann R, Rush AJ. The effects of vagus nerve stimulation on sleep EEG in depression: a preliminary report. J Psychosom Res. May. 2003;54(5):475-82. [pmid: 12726905].
58 Aronson R, Offman HJ, Joffe RT, Naylor CD. Triiodothyronine augmentation in the treatment of refractory depression. A meta-analysis. Arch Gen Psychiatry. Sep. 1996;53(9):842-8. [pmid: 8792761].
59 Aronson TA, Shukla S, Hoff A, Cook B. Proposed delusional depression subtypes: preliminary evidence from a retrospective study of phenomenology and treatment course. J Affect Disord. Jan-Feb. 1988;14(1):69-74. [pmid: 2892870].
60 Artigas F, Romero L, de Montigny C, Blier P. Acceleration of the effect of selected antidepressant drugs in major depression by 5-HT1A antagonists. Trends Neurosci. Sep. 1996;19(9):378-83. [pmid: 8873352].
61 Ashton AK. Depressive relapse after vagal nerve stimulator explantation. Am J Psychiatry. Jun. 2010;167(6):719-20. [pmid: 20516167].
62 Asnis GM, Halbreich U, Nathan RS, Ostrow L, Novacenko H, Endicott J, et al. The dexamethasone suppression test in depressive illness: clinical correlates. Psychoneuroendocrinology. 1982;7(4):295-301. [pmid: 6820157].
63 Austin MP, Souza FG, Goodwin GM. Lithium augmentation in antidepressant-resistant patients. A quantitative analysis. Br J Psychiatry. Oct. 1991;159:510-4. [pmid: 1836411].
64 Avery DH, Claypoole K, Robinson L, Neumaier JF, Dunner DL, Scheele L, et al. Repetitive transcranial magnetic stimulation in the treatment of medication-resistant depression: preliminary data. J Nerv Ment Dis. Feb. 1999;187(2):114-7. [pmid: 10067953].
65 Avery DH, Holtzheimer PE 3rd, Fawaz W, Russo J, Neumaier J, Dunner DL, et al. A controlled study of repetitive transcranial magnetic stimulation in medication-resistant major depression. Biol Psychiatry. Jan. 15. 2006;59(2):187-94. [pmid: 16139808].
66 Avery DH, Holtzheimer PE 3rd, Fawaz W, Russo J, Neumaier J, Dunner DL, et al. Transcranial magnetic stimulation reduces pain in patients with major depression: a sham-controlled study. J Nerv Ment Dis. May. 2007;195(5):378-81. [pmid: 17502802].
67 Avery DH, Isenberg KE, Sampson SM, Janicak PG, Lisanby SH, Maixner DF, et al. Transcranial magnetic stimulation in the acute treatment of major depressive disorder: clinical response in an open-label extension trial. J Clin Psychiatry. Mar. 2008;69(3):441-51. [pmid: 18294022].
68 Avramov MN, Husain MM, White PF. The comparative effects of methohexital, propofol, and etomidate for electroconvulsive therapy. Anesth Analg. 1995;81(3):596-602. [pmid: 7653829].
69 Awata S, Konno M, Kawashima R, Suzuki K, Sato T, Matsuoka H, et al. Changes in regional cerebral blood flow abnormalities in late-life depression following response to electroconvulsive therapy. Psychiatry Clin Neurosci. Feb. 2002;56(1):31-40. [pmid: 11929569].
70 Aymard N, Viala A, Baldacci C, Smagghe PO, Vacheron MN, Caroli F. Pharmacoclinical strategy in neuroleptic resistant schizophrenic patients treated by clozapine: clinical evolution, concentration of plasma and red blood cell clozapine and desmethylclozapine, whole blood serotonin and tryptophan. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 1999;23(1):25-41. [pmid: 10368854].
71 Azuma H, Fujita A, Sato K, Arahata K, Otsuki K, Hori M, et al. Postictal cardiovascular response predicts therapeutic efficacy of electroconvulsive therapy for depression. Psychiatry Clin Neurosci. Jun. 2007;61(3):290-4. [pmid: 17472598].
72 Babigian HM, Guttmacher LB. Epidemiologic considerations in electroconvulsive therapy. Arch Gen Psychiatry. Mar. 1984;41(3):246-53. [pmid: 6703844].
73 Bader CD, Dunner DL. Antidepressant-induced hypomania in treatment-resistant depression. J Psychiatr Pract. Jul. 2007;13(4):233-7. [pmid: 17667735].
74 Baeken C, De Raedt R, Van Hove C, Clerinx P, De Mey J, Bossuyt A. HF-rTMS treatment in medication-resistant melancholic depression: results from 18FDG-PET brain imaging. CNS Spectr. Aug. 2009;14(8):439-48. [pmid: 19890238].
75 Baetz M, Bowen RC. Efficacy of divalproex sodium in patients with panic disorder and mood instability who have not responded to conventional therapy. Can J Psychiatry. Feb. 1998;43(1):73-7. [pmid: 9494751].
76 Baghai TC, Marcuse A, Brosch M, Schule C, Eser D, Nothdurfter C, et al. The influence of concomitant antidepressant medication on safety, tolerability and clinical effectiveness of electroconvulsive therapy. World J Biol Psychiatry. 2006;7(2):82-90. [pmid: 16684680].
77 Baghai TC, Moller HJ. Electroconvulsive therapy and its different indications. Dialogues Clin Neurosci. 2008;10(1):105-17. [pmid: 18472488].
78 Bailey KP. Treating treatment-resistant depression. Whether to switch, augment, or combine therapies. J Psychosoc Nurs Ment Health Serv. Jun. 2003;41(6):14-20.
79 Bailine SH, Rifkin A, Kayne E, Selzer JA, Vital-Herne J, Blieka M, et al. Comparison of bifrontal and bitemporal ECT for major depression. Am J Psychiatry. Jan. 2000;157(1):121-3. [pmid: 10618025].
80 Bair MJ, Robinson RL, Katon W, Kroenke K. Depression and pain comorbidity: a literature review. Arch Intern Med. Nov. 10. 2003;163(20):2433-45. [pmid: 14609780].
81 Bajbouj M, Brakemeier EL, Schubert F, Lang UE, Neu P, Schindowski C, et al. Repetitive transcranial magnetic stimulation of the dorsolateral prefrontal cortex and cortical excitability in patients with major depressive disorder. Exp Neurol. Dec. 2005;196(2):332-8. [pmid: 16194530].
82 Bajbouj M, Gallinat J, Lang UE, Hellen F, Vesper J, Lisanby SH, et al. Motor cortex excitability after vagus nerve stimulation in major depression. J Clin Psychopharmacol. Apr. 2007;27(2):156-9. [pmid: 17414238].
83 Bajbouj M, Gallinat J, Lang UE, Neu P, Niehaus L. Motorcortical excitability after electroconvulsive therapy in patients with major depressive disorder. Suppl Clin Neurophysiol. 2003;56:433-40. [pmid: 14677419].
84 Bajbouj M, Lang UE, Niehaus L, Hellen FE, Heuser I, Neu P. Effects of right unilateral electroconvulsive therapy on motor cortical excitability in depressive patients. J Psychiatr Res. Jun. 2006;40(4):322-7. [pmid: 16137698].
85 Bajbouj M, Lisanby SH, Lang UE, Danker-Hopfe H, Heuser I, Neu P. Evidence for impaired cortical inhibition in patients with unipolar major depression. Biol Psychiatry. Mar. 1. 2006;59(5):395-400. [pmid: 16197927].
86 Bajwa S, Bermpohl F, Rigonatti SP, Pascual-Leone A, Boggio PS, Fregni F. Impaired interhemispheric interactions in patients with major depression. J Nerv Ment Dis. Sep. 2008;196(9):671-7. [pmid: 18791428].
87 Baldessarini RJ. Current status of antidepressants: clinical pharmacology and therapy. J Clin Psychiatry. Apr. 1989;50(4):117-26. [pmid: 2647712].
88 Baldwin RC, Simpson S. Treatment resistant depression in the elderly: a review of its conceptualisation, management and relationship to organic brain disease. J Affect Disord. Dec. 1997;46(3):163-73. [pmid: 9547114].
89 Barbee JG, Conrad EJ, Jamhour NJ. The effectiveness of olanzapine, risperidone, quetiapine, and ziprasidone as augmentation agents in treatment-resistant major depressive disorder. J Clin Psychiatry. Jul. 2004;65(7):975-81. [pmid: 15291687].
90 Bares M, Brunovsky M, Kopecek M, Stopkova P, Novak T, Kozeny J, et al. Changes in QEEG prefrontal cordance as a predictor of response to antidepressants in patients with treatment resistant depressive disorder: a pilot study. J Psychiatr Res. Apr-Jun. 2007;41(3-4):319-25. [pmid: 16889798].
91 Bares M, Novak T, Kopecek M, Stopkova P, Sos P. Is combined treatment more effective than switching to monotherapy in patients with resistant depression? A retrospective study. Neuro Endocrinol Lett. 2009;30(6):723-8. [pmid: 20038931].
92 Barker WA, Scott J, Eccleston D. The Newcastle chronic depression study: results of a treatment regime. Int Clin Psychopharmacol. Jul. 1987;2(3):261-72. [pmid: 3121718].
93 Battersby M, Ben-Tovim D, Eden J. Electroconvulsive therapy: a study of attitudes and attitude change after seeing an educational video. Aust N Z J Psychiatry. Dec. 1993;27(4):613-9. [pmid: 8135686].
94 Bauer M, Adli M, Baethge C, Berghofer A, Sasse J, Heinz A, et al. Lithium augmentation therapy in refractory depression: clinical evidence and neurobiological mechanisms. Can J Psychiatry. Aug. 2003;48(7):440-8. [pmid: 12971013].
95 Bauer M, Adli M, Bschor T, Pilhatsch M, Pfennig A, Sasse J, et al. Lithium's emerging role in the treatment of refractory major depressive episodes: augmentation of antidepressants. Neuropsychobiology. 2010;62(1):36-42. [pmid: 20453533].
96 Bauer M, Baur H, Berghofer A, Strohle A, Hellweg R, Muller-Oerlinghausen B, et al. Effects of supraphysiological thyroxine administration in healthy controls and patients with depressive disorders. J Affect Disord. Apr. 2002;68(2-3):285-94. [pmid: 12063156].
97 Bauer M, Beaulieu S, Dunner DL, Lafer B, Kupka R. Rapid cycling bipolar disorder--diagnostic concepts. Bipolar Disord. Feb. 2008;10(1 Pt 2):153-62. [pmid: 18199234].
98 Bauer M, Dopfmer S. Lithium augmentation in treatment-resistant depression: meta-analysis of placebo-controlled studies. J Clin Psychopharmacol. Oct. 1999;19(5):427-34. [pmid: 10505584].
99 Bauer M, Forsthoff A, Baethge C, Adli M, Berghofer A, Dopfmer S, et al. Lithium augmentation therapy in refractory depression-update 2002. Eur Arch Psychiatry Clin Neurosci. Jun. 2003;253(3):132-9. [pmid: 12904977].
100 Bauer M, Pfennig A, Linden M, Smolka MN, Neu P, Adli M. Efficacy of an algorithm-guided treatment compared with treatment as usual: a randomized, controlled study of inpatients with depression. J Clin Psychopharmacol. Aug. 2009;29(4):327-33. [pmid: 19593170].
101 Bauer M, Tharmanathan P, Volz HP, Moeller HJ, Freemantle N. The effect of venlafaxine compared with other antidepressants and placebo in the treatment of major depression: a meta-analysis. Eur Arch Psychiatry Clin Neurosci. Apr. 2009;259(3):172-85. [pmid: 19165525].
102 Bauer ME, Papadopoulos A, Poon L, Perks P, Lightman SL, Checkley S, et al. Dexamethasone-induced effects on lymphocyte distribution and expression of adhesion molecules in treatment-resistant depression. Psychiatry Res. Dec. 15. 2002;113(1-2):1-15. [pmid: 12467941].
103 Bauer ME, Papadopoulos A, Poon L, Perks P, Lightman SL, Checkley S, et al. Altered glucocorticoid immunoregulation in treatment resistant depression. Psychoneuroendocrinology. Jan. 2003;28(1):49-65. [pmid: 12445836].
104 Baumann P, Nil R, Souche A, Montaldi S, Baettig D, Lambert S, et al. A double-blind, placebo-controlled study of citalopram with and without lithium in the treatment of therapy-resistant depressive patients: a clinical, pharmacokinetic, and pharmacogenetic investigation. J Clin Psychopharmacol. Aug. 1996;16(4):307-14. [pmid: 8835706].
105 Baune BT, Caliskan S, Todder D. Effects of adjunctive antidepressant therapy with quetiapine on clinical outcome, quality of sleep and daytime motor activity in patients with treatment-resistant depression. Hum Psychopharmacol. Jan. 2007;22(1):1-9. [pmid: 17191266].
106 Bean GJ, Marchese V, Martin BA. Electric stimulus energy and the clinical response to electroconvulsive therapy. Can J Psychiatry. Nov. 1991;36(9):637-44. [pmid: 1773399].
107 Bearn J, Franey C, Arendt J, Checkley SA. A study of the effects of desipramine treatment alone and in combination with L-triiodothyronine on 6-sulphatoxymelatonin excretion in depressed patients. Br J Psychiatry. Sep. 1989;155:341-7. [pmid: 2611544].
108 Beasley CM Jr, Sayler ME, Cunningham GE, Weiss AM, Masica DN. Fluoxetine in tricyclic refractory major depressive disorder. J Affect Disord. Nov. 1990;20(3):193-200. [pmid: 2148340].
109 Beliles K, Stoudemire A. Psychopharmacologic treatment of depression in the medically ill. Psychosomatics. May-Jun. 1998;39(3):S2-19. [pmid: 9664784].
110 Benbow SM. Management of depression in the elderly. Br J Hosp Med. 1992 Dec 2-1993 Jan 5. 48(11):726-31. [pmid: 1467817].
111 Bergsholm P, Larsen JL, Rosendahl K, Holsten F. Electroconvulsive therapy and cerebral computed tomography. A prospective study. Acta Psychiatr Scand. Dec. 1989;80(6):566-72. [pmid: 2618780].
112 Berk M, Copolov DL, Dean O, Lu K, Jeavons S, Schapkaitz I, et al. N-acetyl cysteine for depressive symptoms in bipolar disorder--a double-blind randomized placebo-controlled trial. Biol Psychiatry. Sep. 15. 2008;64(6):468-75. [pmid: 18534556].
113 Berlim MT, Fleck MP, Turecki G. Current trends in the assessment and somatic treatment of resistant/refractory major depression: an overview. Ann Med. 2008;40(2):149-59. [pmid: 18293145].
114 Berlim MT, Turecki G. What is the meaning of treatment resistant/refractory major depression (TRD)? A systematic review of current randomized trials. Eur Neuropsychopharmacol. Nov. 2007;17(11):696-707. [pmid: 17521891].
115 Berlim MT, Turecki G. Definition, assessment, and staging of treatment-resistant refractory major depression: a review of current concepts and methods. Can J Psychiatry. Jan. 2007;52(1):46-54. [pmid: 17444078].
116 Bermack JE, Debonnel G. The role of sigma receptors in depression. J Pharmacol Sci. Mar. 2005;97(3):317-36. [pmid: 15750289].
117 Berman RM, Narasimhan M, Charney DS. Treatment-refractory depression: definitions and characteristics. Depress Anxiety. 1997;5(4):154-64. [pmid: 9338108].
118 Bermpohl F, Fregni F, Boggio PS, Thut G, Northoff G, Otachi PT, et al. Effect of low-frequency transcranial magnetic stimulation on an affective go/no-go task in patients with major depression: role of stimulation site and depression severity. Psychiatry Res. Jan. 30. 2006;141(1):1-13. [pmid: 16352348].
119 Berrios GE, Bulbena A, Bakshi N, Dening TR, Jenaway A, Markar H, et al. Feelings of guilt in major depression. Conceptual and psychometric aspects. Br J Psychiatry. Jun. 1992;160:781-7. [pmid: 1617361].
120 Beutler LE, Engle D, Mohr D, Daldrup RJ, Bergan J, Meredith K, et al. Predictors of differential response to cognitive, experiential, and self-directed psychotherapeutic procedures. J Consult Clin Psychol. Apr. 1991;59(2):333-40. [pmid: 2030196].
121 Birkenhager TK, Renes JW, Pluijms EM. One-year follow-up after successful ECT: a naturalistic study in depressed inpatients. J Clin Psychiatry. Jan. 2004;65(1):87-91. [pmid: 14744175].
122 Birkenhager TK, van den Broek WW, Moleman P, Bruijn JA. Outcome of a 4-step treatment algorithm for depressed inpatients. J Clin Psychiatry. Aug. 2006;67(8):1266-71. [pmid: 16965206].
123 Birkenhager TK, van den Broek WW, Mulder PG, Bruijn JA, Moleman P. Efficacy and tolerability of tranylcypromine versus phenelzine: a double-blind study in antidepressant-refractory depressed inpatients. J Clin Psychiatry. Nov. 2004;65(11):1505-10. [pmid: 15554763].
124 Birkenhager TK, Vegt M, Nolen WA. An open study of triiodothyronine augmentation of tricyclic antidepressants in inpatients with refractory depression. Pharmacopsychiatry. Jan. 1997;30(1):23-6. [pmid: 9065966].
125 Black DW, Goldstein RB, Nasrallah A, Winokur G. The prediction of recovery using a multivariate model in 1471 depressed inpatients. Eur Arch Psychiatry Clin Neurosci. 1991;241(1):41-5. [pmid: 1832304].
126 Black DW, Winokur G, Nasrallah A. Treatment and outcome in secondary depression: a naturalistic study of 1087 patients. J Clin Psychiatry. Nov. 1987;48(11):438-41. [pmid: 3680184].
127 Black DW, Winokur G, Nasrallah A. The treatment of depression: electroconvulsive therapy v antidepressants: a naturalistic evaluation of 1,495 patients. Compr Psychiatry. Mar-Apr. 1987;28(2):169-82. [pmid: 3829660].
128 Blazer D. New concepts in the diagnosis and management of depression. Compr Ther. Apr. 1988;14(4):56-60. [pmid: 3130216].
129 Blier P, Bergeron R. Effectiveness of pindolol with selected antidepressant drugs in the treatment of major depression. J Clin Psychopharmacol. Jun. 1995;15(3):217-22. [pmid: 7636000].
130 Blier P, Bergeron R. Early onset of therapeutic action in depression and greater efficacy of antidepressant treatments: are they related?. Int Clin Psychopharmacol. Jul. 3. 1997;12:S21-8. [pmid: 9347389].
131 Blier P, Bergeron R. The use of pindolol to potentiate antidepressant medication. J Clin Psychiatry. 5. 1998;59:16-23. discussion 4-5. [pmid: 9635544].
132 Bobo WV, Shelton RC. Fluoxetine and olanzapine combination therapy in treatment-resistant major depression: review of efficacy and safety data. Expert Opin Pharmacother. Sep. 2009;10(13):2145-59. [pmid: 19640209].
133 Bobo WV, Shelton RC. Efficacy, safety and tolerability of Symbyax for acute-phase management of treatment-resistant depression. Expert Rev Neurother. May. 2010;10(5):651-70. [pmid: 20420487].
134 Bocchio-Chiavetto L, Miniussi C, Zanardini R, Gazzoli A, Bignotti S, Specchia C, et al. 5-HTTLPR and BDNF Val66Met polymorphisms and response to rTMS treatment in drug resistant depression. Neurosci Lett. May. 30. 2008;437(2):130-4. [pmid: 18450378].
135 Bocchio-Chiavetto L, Zanardini R, Bortolomasi M, Abate M, Segala M, Giacopuzzi M, et al. Electroconvulsive Therapy (ECT) increases serum Brain Derived Neurotrophic Factor (BDNF) in drug resistant depressed patients. Eur Neuropsychopharmacol. Dec. 2006;16(8):620-4. [pmid: 16757154].
136 Bodenlos JS, Kose S, Borckardt JJ, Nahas Z, Shaw D, O'Neil PM, et al. Vagus nerve stimulation acutely alters food craving in adults with depression. Appetite. Mar. 2007;48(2):145-53. [pmid: 17081655].
137 Boggio PS, Fregni F, Bermpohl F, Mansur CG, Rosa M, Rumi DO, et al. Effect of repetitive TMS and fluoxetine on cognitive function in patients with Parkinson's disease and concurrent depression. Mov Disord. Sep. 2005;20(9):1178-84. [pmid: 15895421].
138 Bohning DE, Lomarev MP, Denslow S, Nahas Z, Shastri A, George MS. Feasibility of vagus nerve stimulation-synchronized blood oxygenation level-dependent functional MRI. Invest Radiol. Aug. 2001;36(8):470-9. [pmid: 11500598].
139 Bondolfi G, Chautems C, Rochat B, Bertschy G, Baumann P. Non-response to citalopram in depressive patients: pharmacokinetic and clinical consequences of a fluvoxamine augmentation. Psychopharmacology (Berl). Dec. 1996;128(4):421-5. [pmid: 8986013].
140 Bonne O, Krausz Y, Gorfine M, Karger H, Gelfin Y, Shapira B, et al. Cerebral hypoperfusion in medication resistant, depressed patients assessed by Tc99m HMPAO SPECT. J Affect Disord. Dec. 16. 1996;41(3):163-71. [pmid: 8988448].
141 Bonner D, Howard R. Treatment-resistant depression in the elderly. Int Psychogeriatr. Suppl. 1995;7:83-94. [pmid: 8580395].
142 Bonnet U. Moclobemide: therapeutic use and clinical studies. CNS Drug Rev. Spring. 2003;9(1):97-140. [pmid: 12595913].
143 Borckardt JJ, Kozel FA, Anderson B, Walker A, George MS. Vagus nerve stimulation affects pain perception in depressed adults. Pain Res Manag. Spring. 2005;10(1):9-14. [pmid: 15782242].
144 Bortolomasi M, Minelli A, Fuggetta G, Perini M, Comencini S, Fiaschi A, et al. Long-lasting effects of high frequency repetitive transcranial magnetic stimulation in major depressed patients. Psychiatry Res. Mar. 30. 2007;150(2):181-6. [pmid: 17303249].
145 Bosboom PR, Deijen JB. Age-related cognitive effects of ECT and ECT-induced mood improvement in depressive patients. Depress Anxiety. 2006;23(2):93-101. [pmid: 16400627].
146 Bosworth HB, Hays JC, George LK, Steffens DC. Psychosocial and clinical predictors of unipolar depression outcome in older adults. Int J Geriatr Psychiatry. Mar. 2002;17(3):238-46. [pmid: 11921152].
147 Bosworth HB, McQuoid DR, George LK, Steffens DC. Time-to-remission from geriatric depression: psychosocial and clinical factors. Am J Geriatr Psychiatry. Sep-Oct. 2002;10(5):551-9. [pmid: 12213689].
148 Botteron KN, Geller B. Refractory depression in children and adolescents. Depress Anxiety. 1997;5(4):212-23. [pmid: 9338113].
149 Bowden CL. Treatment options for bipolar depression. J Clin Psychiatry. 1. 2005;66:3-6.
150 Bradvik L, Berglund M. Long-term treatment and suicidal behavior in severe depression: ECT and antidepressant pharmacotherapy may have different effects on the occurrence and seriousness of suicide attempts. Depress Anxiety. 2006;23(1):34-41. [pmid: 16315268].
151 Brakemeier EL, Luborzewski A, Danker-Hopfe H, Kathmann N, Bajbouj M. Positive predictors for antidepressive response to prefrontal repetitive transcranial magnetic stimulation (rTMS). J Psychiatr Res. Aug. 2007;41(5):395-403. [pmid: 16554071].
152 Brakemeier EL, Wilbertz G, Rodax S, Danker-Hopfe H, Zinka B, Zwanzger P, et al. Patterns of response to repetitive transcranial magnetic stimulation (rTMS) in major depression: replication study in drug-free patients. J Affect Disord. May. 2008;108(1-2):59-70. [pmid: 17963846].
153 Brandon S, Cowley P, McDonald C, Neville P, Palmer R, Wellstood-Eason S. Electroconvulsive therapy: results in depressive illness from the Leicestershire trial. Br Med J (Clin Res Ed). Jan. 7. 1984;288(6410):22-5.
154 Bretlau LG, Lunde M, Lindberg L, Unden M, Dissing S, Bech P. Repetitive transcranial magnetic stimulation (rTMS) in combination with escitalopram in patients with treatment-resistant major depression: a double-blind, randomised, sham-controlled trial. Pharmacopsychiatry. 2008:41-7.
155 Brink CB, Harvey BH, Brand L. Tianeptine: a novel atypical antidepressant that may provide new insights into the biomolecular basis of depression. Recent Pat CNS Drug Discov. Jan. 2006;1(1):29-41. [pmid: 18221189].
156 Brockington IF, Kendell RE, Wainwright S. Depressed patients with schizophrenic or paranoid symptoms. Psychol Med. Nov. 1980;10(4):665-75. [pmid: 6111099].
157 Brodaty H, Berle D, Hickie I, Mason C. “Side effects” of ECT are mainly depressive phenomena and are independent of age. J Affect Disord. Oct. 2001;66(2-3):237-45. [pmid: 11578677].
158 Brodaty H, Hickie I, Mason C, Prenter L. A prospective follow-up study of ECT outcome in older depressed patients. J Affect Disord. Nov. 2000;60(2):101-11. [pmid: 10967369].
159 Brown AJ. Depression and insulin resistance: applications to polycystic ovary syndrome. Clin Obstet Gynecol. Sep. 2004;47(3):592-6. [pmid: 15326421].
160 Brusov OS, Fomenko AM, Katasonov AB. Human plasma inhibitors of platelet serotonin uptake and imipramine receptor binding: extraction and heterogeneity. Biol Psychiatry. Mar. 1985;20(3):235-44. [pmid: 2983787].
161 Bschor T. Therapy-resistant depression. Expert Rev Neurother. Jan. 2010;10(1):77-86. [pmid: 20021322].
162 Bschor T, Baethge C, Adli M, Eichmann U, Ising M, Uhr M, et al. Association between response to lithium augmentation and the combined DEX/CRH test in major depressive disorder. J Psychiatr Res. Mar-Apr. 2003;37(2):135-43. [pmid: 12842167].
163 Bschor T, Bauer M. Efficacy and mechanisms of action of lithium augmentation in refractory major depression. Curr Pharm Des. 2006;12(23):2985-92. [pmid: 16918427].
164 Bschor T, Berghofer A, Strohle A, Kunz D, Adli M, Muller-Oerlinghausen B, et al. How long should the lithium augmentation strategy be maintained? A 1-year follow-up of a placebo-controlled study in unipolar refractory major depression. J Clin Psychopharmacol. Aug. 2002;22(4):427-30. [pmid: 12172345].
165 Bschor T, Canata B, Muller-Oerlinghausen B, Bauer M. Predictors of response to lithium augmentation in tricyclic antidepressant-resistant depression. J Affect Disord. May. 2001;64(2-3):261-5. [pmid: 11313093].
166 Bschor T, Lewitzka U, Sasse J, Adli M, Koberle U, Bauer M. Lithium augmentation in treatment-resistant depression: clinical evidence, serotonergic and endocrine mechanisms. Pharmacopsychiatry. Nov. 3. 2003;36:S230-4. [pmid: 14677084].
167 Bulbena A, Berrios GE. Cognitive function in the affective disorders: a prospective study. Psychopathology. 1993;26(1):6-12. [pmid: 8511231].
168 Bundy BD, Hewer W, Andres FJ, Gass P, Sartorius A. Influence of anesthetic drugs and concurrent psychiatric medication on seizure adequacy during electroconvulsive therapy. J Clin Psychiatry. Jun. 2010;71(6):775-7. [pmid: 20051218].
169 Burke MJ, Husain MM. Concomitant use of vagus nerve stimulation and electroconvulsive therapy for treatment-resistant depression. J Ect. Sep. 2006;22(3):218-22. [pmid: 16957540].
170 Burton SW. A review of fluvoxamine and its uses in depression. Int Clin Psychopharmacol. Dec. 3. 1991;6:1-17. discussion -21. [pmid: 1806631].
171 Bustin J, Rapoport MJ, Krishna M, Matusevich D, Finkelsztein C, Strejilevich S, et al. Are patients' attitudes towards and knowledge of electroconvulsive therapy transcultural? A multi-national pilot study. Int J Geriatr Psychiatry. May. 2008;23(5):497-503. [pmid: 17997511].
172 Butterfield NN, Graf P, Macleod BA, Ries CR, Zis AP. Propofol reduces cognitive impairment after electroconvulsive therapy. J Ect. Mar. 2004;20(1):3-9. [pmid: 15087989].
173 Cadieux RJ. Practical management of treatment-resistant depression. Am Fam Physician. Dec. 1998;58(9):2059-62. [pmid: 9861879].
174 Cain RA. Navigating the Sequenced Treatment Alternatives to Relieve Depression (STAR*D) study: practical outcomes and implications for depression treatment in primary care. Prim Care. Sep. 2007;34(3):505-19. vi. [pmid: 17868757].
175 Calev A, Nigal D, Shapira B, Tubi N, Chazan S, Ben-Yehuda Y, et al. Early and long-term effects of electroconvulsive therapy and depression on memory and other cognitive functions. J Nerv Ment Dis. Sep. 1991;179(9):526-33. [pmid: 1919554].
176 Caley CF, Weber SS. Paroxetine: a selective serotonin reuptake inhibiting antidepressant. Ann Pharmacother. Oct. 1993;27(10):1212-22. [pmid: 8251692].
177 Calfa G, Kademian S, Ceschin D, Vega G, Rabinovich GA, Volosin M. Characterization and functional significance of glucocorticoid receptors in patients with major depression: modulation by antidepressant treatment. Psychoneuroendocrinology. Jul. 2003;28(5):687-701. [pmid: 12727135].
178 Cappiello A, McDougle CJ, Delgado PL, Malison RT, Jatlow P, Charney DS, et al. Lithium and desipramine versus desipramine alone in the treatment of severe major depression: a preliminary study. Int Clin Psychopharmacol. Sep. 1998;13(5):191-8. [pmid: 9817623].
179 Cappiello A, McDougle CJ, Malison RT, Heninger GR, Price LH. Yohimbine augmentation of fluvoxamine in refractory depression: a single-blind study. Biol Psychiatry. Dec. 1. 1995;38(11):765-7. [pmid: 8580232].
180 Cardoner N, Pujol J, Vallejo J, Urretavizcaya M, Deus J, Lopez-Sala A, et al. Enlargement of brain cerebrospinal fluid spaces as a predictor of poor clinical outcome in melancholia. J Clin Psychiatry. Jun. 2003;64(6):691-7. [pmid: 12823084].
181 Carl C, Engelhardt W, Teichmann G, Fuchs G. Open comparative study with treatment-refractory depressed patients: electroconvulsive therapy--anesthetic therapy with isoflurane (preliminary report). Pharmacopsychiatry. Nov. 1988;21(6):432-3. [pmid: 3244786].
182 Carmody TJ, Rush AJ, Bernstein IH, Brannan S, Husain MM, Trivedi MH. Making clinicians lives easier: guidance on use of the QIDS self-report in place of the MADRS. J Affect Disord. Oct. 2006;95(1-3):115-8. [pmid: 16707162].
183 Carney RM, Blumenthal JA, Freedland KE, Youngblood M, Veith RC, Burg MM, et al. Depression and late mortality after myocardial infarction in the Enhancing Recovery in Coronary Heart Disease (ENRICHD) study. Psychosom Med. Jul-Aug. 2004;66(4):466-74. [pmid: 15272090].
184 Carney RM, Freedland KE. Treatment-resistant depression and mortality after acute coronary syndrome. Am J Psychiatry. Apr. 2009;166(4):410-7. [pmid: 19289455].
185 Carpenter LL. Neurostimulation in resistant depression. J Psychopharmacol. May. 2006;20(3 Suppl):35-40. [pmid: 16644770].
186 Carpenter LL, Bayat L, Moreno F, Kling MA, Price LH, Tyrka AR, et al. Decreased cerebrospinal fluid concentrations of substance P in treatment-resistant depression and lack of alteration after acute adjunct vagus nerve stimulation therapy. Psychiatry Res. Jan. 15. 2008;157(1-3):123-9. [pmid: 17976740].
187 Carpenter LL, Friehs GM, Price LH. Cervical vagus nerve stimulation for treatment-resistant depression. Neurosurg Clin N Am. Apr. 2003;14(2):275-82. [pmid: 12856494].
188 Carpenter LL, Jocic Z, Hall JM, Rasmussen SA, Price LH. Mirtazapine augmentation in the treatment of refractory depression. J Clin Psychiatry. Jan. 1999;60(1):45-9. [pmid: 10074878].
189 Carretero B, Martin MJ, Juan A, Pradana ML, Martin B, Carral M, et al. Low-frequency transcranial magnetic stimulation in patients with fibromyalgia and major depression. Pain Med. May-Jun. 2009;10(4):748-53. [pmid: 19460131].
190 Carvalho AF, Cavalcante JL, Castelo MS, Lima MC. Augmentation strategies for treatment-resistant depression: a literature review. J Clin Pharm Ther. Oct. 2007;32(5):415-28. [pmid: 17875106].
191 Carvalho AF, Machado JR, Cavalcante JL. Augmentation strategies for treatment-resistant depression. Curr Opin Psychiatry. Jan. 2009;22(1):7-12. [pmid: 19122528].
192 Carvalho LA, Juruena MF, Papadopoulos AS, Poon L, Kerwin R, Cleare AJ, et al. Clomipramine in vitro reduces glucocorticoid receptor function in healthy subjects but not in patients with major depression. Neuropsychopharmacology. Dec. 2008;33(13):3182-9. [pmid: 18368033].
193 Casey DA. Depression in the elderly. South Med J. May. 1994;87(5):559-63. [pmid: 8178211].
194 Casey P, Meagher D, Butler E. Personality, functioning, and recovery from major depression. J Nerv Ment Dis. Apr. 1996;184(4):240-5. [pmid: 8604034].
195 Cassidy F. Antidepressant treatment practice in the face of STAR*D and STEP-BD. Bipolar Disord. Dec. 2008;10(8):973-4. [pmid: 19594512].
196 Cassidy F, Murry E, Weiner RD, Carroll BJ. Lack of relapse with tryptophan depletion following successful treatment with ECT. Am J Psychiatry. Aug. 1997;154(8):1151-2. [pmid: 9247406].
197 Cassidy F, Weiner RD, Cooper TB, Carroll BJ. Antidepressant response to electroconvulsive therapy is sustained after catecholamine depletion. Prog Neuropsychopharmacol Biol Psychiatry. Aug. 1. 2009;33(5):872-4. [pmid: 19376184].
198 Chaimowitz GA, Links PS, Padgett RW, Carr AC. Treatment-resistant depression: a survey of practice habits of Canadian psychiatrists. Can J Psychiatry. Jun. 1991;36(5):353-6. [pmid: 1679373].
199 Chambers AS, Allen JJ. Vagal tone as an indicator of treatment response in major depression. Psychophysiology. Nov. 2002;39(6):861-4. [pmid: 12462513].
200 Charney DS, Price LH, Heninger GR. Desipramine-yohimbine combination treatment of refractory depression. Implications for the beta-adrenergic receptor hypothesis of antidepressant action. Arch Gen Psychiatry. Dec. 1986;43(12):1155-61. [pmid: 3022664].
201 Chavel SM, Westerveld M, Spencer S. Long-term outcome of vagus nerve stimulation for refractory partial epilepsy. Epilepsy Behav. Jun. 2003;4(3):302-9. [pmid: 12791333].
202 Chehil S, Devarajan S, Dursun SM. Pharmacologic management of refractory depression. Can Fam Physician. Jan. 2001;47:50-2. [pmid: 11212433].
203 Chen YC, Lin WW, Chen YJ, Mao WC, Hung YJ. Antidepressant effects on insulin sensitivity and proinflammatory cytokines in the depressed males. Mediators Inflamm. 2010;2010:573594. [pmid: 20490354].
204 Chen YC, Shen YC, Hung YJ, Chou CH, Yeh CB, Perng CH. Comparisons of glucose-insulin homeostasis following maprotiline and fluoxetine treatment in depressed males. J Affect Disord. Nov. 2007;103(1-3):257-61. [pmid: 17320192].
205 Chistyakov AV, Kaplan B, Rubichek O, Kreinin I, Koren D, Feinsod M, et al. Antidepressant effects of different schedules of repetitive transcranial magnetic stimulation vs. clomipramine in patients with major depression: relationship to changes in cortical excitability. Int J Neuropsychopharmacol. Jun. 2005;8(2):223-33. [pmid: 15569397].
206 Chistyakov AV, Kaplan B, Rubichek O, Kreinin I, Koren D, Hafner H, et al. Effect of electroconvulsive therapy on cortical excitability in patients with major depression: a transcranial magnetic stimulation study. Clin Neurophysiol. Feb. 2005;116(2):386-92. [pmid: 15661116].
207 Chistyakov AV, Rubicsek O, Kaplan B, Zaaroor M, Klein E. Safety, tolerability and preliminary evidence for antidepressant efficacy of theta-burst transcranial magnetic stimulation in patients with major depression. Int J Neuropsychopharmacol. Apr. 2010;13(3):387-93. [pmid: 20128955].
208 Choi MJ, Kang RH, Lim SW, Oh KS, Lee MS. Brain-derived neurotrophic factor gene polymorphism (Val66Met) and citalopram response in major depressive disorder. Brain Res. Nov. 6. 2006;1118(1):176-82. [pmid: 16979146].
209 Chow TW, Mendez MF. Goals in symptomatic pharmacologic management of frontotemporal lobar degeneration. Am J Alzheimers Dis Other Demen. Sep-Oct. 2002;17(5):267-72. [pmid: 12392261].
210 Cinar S, Oude Voshaar RC, Janzing JG, Birkenhager TK, Buitelaar JK, van den Broek WW. The course of depressive symptoms in unipolar depressive disorder during electroconvulsive therapy: a latent class analysis. J Affect Disord. Jul. 2010;124(1-2):141-7. [pmid: 19931917].
211 Cipriani A, Smith K, Burgess S, Carney S, Goodwin G, Geddes J. Lithium versus antidepressants in the long-term treatment of unipolar affective disorder. Cochrane Database Syst Rev. 2006;(4):CD003492. [pmid: 17054174].
212 Clark CP, Alexopoulos GS, Kaplan J. Prolactin release and clinical response to electroconvulsive therapy in depressed geriatric inpatients: a preliminary report. Convuls Ther. Mar. 1995;11(1):24-31. [pmid: 7796064].
213 Coffey CE, Figiel GS, Djang WT, Sullivan DC, Herfkens RJ, Weiner RD. Effects of ECT on brain structure: a pilot prospective magnetic resonance imaging study. Am J Psychiatry. Jun. 1988;145(6):701-6. [pmid: 3369556].
214 Coffey CE, Figiel GS, Weiner RD, Saunders WB. Caffeine augmentation of ECT. Am J Psychiatry. May. 1990;147(5):579-85. [pmid: 2183632].
215 Coffey CE, Weiner RD, Djang WT, Figiel GS, Soady SA, Patterson LJ, et al. Brain anatomic effects of electroconvulsive therapy. A prospective magnetic resonance imaging study. Arch Gen Psychiatry. Nov. 1991;48(11):1013-21. [pmid: 1747016].
216 Cohen LJ. A managed care perspective of individualized care. J Manag Care Pharm. Mar. 2004;10(2 Suppl):S16-21. [pmid: 15046546].
217 Cohen MR, Swartz CM. Absence of nimodipine premedication effect on memory after electroconvulsive therapy. Neuropsychobiology. 1990;24(4):165-8. [pmid: 2135706].
218 Cohen RB, Brunoni AR, Boggio PS, Fregni F. Clinical predictors associated with duration of repetitive transcranial magnetic stimulation treatment for remission in bipolar depression: a naturalistic study. J Nerv Ment Dis. Sep. 2010;198(9):679-81. [pmid: 20823731].
219 Cohen Y, Feldinger E, Ogorek D, Weinbroum AA. Increased propofol requirement during succeeding administrations for electroconvulsive therapy. J Clin Anesth. Jun. 2004;16(4):282-5. [pmid: 15261320].
220 Cohn JB. Triazolam treatment of insomnia in depressed patients taking tricyclics. J Clin Psychiatry. Nov. 1983;44(11):401-6. [pmid: 6139364].
221 Cohrs S, Tergau F, Korn J, Becker W, Hajak G. Suprathreshold repetitive transcranial magnetic stimulation elevates thyroid-stimulating hormone in healthy male subjects. J Nerv Ment Dis. Jun. 2001;189(6):393-7. [pmid: 11434640].
222 Cohrs S, Tergau F, Riech S, Kastner S, Paulus W, Ziemann U, et al. High-frequency repetitive transcranial magnetic stimulation delays rapid eye movement sleep. Neuroreport. Oct. 26. 1998;9(15):3439-43. [pmid: 9855295].
223 Coleman EA, Sackeim HA, Prudic J, Devanand DP, McElhiney MC, Moody BJ. Subjective memory complaints prior to and following electroconvulsive therapy. Biol Psychiatry. Mar. 1. 1996;39(5):346-56. [pmid: 8704066].
224 Conca A, Koppi S, König P, Swoboda E, Krecke N. Transcranial magnetic stimulation: a novel antidepressive strategy?. Neuropsychobiology. 1996;34(4):204-7. [pmid: 9121622].
225 Conway CR, Sheline YI, Chibnall JT, George MS, Fletcher JW, Mintun MA. Cerebral blood flow changes during vagus nerve stimulation for depression. Psychiatry Res. Mar. 31. 2006;146(2):179-84. [pmid: 16510266].
226 Cook IA, Leuchter AF, Witte E, Abrams M, Uijtdehaage SH, Stubbeman W, et al. Neurophysiologic predictors of treatment response to fluoxetine in major depression. Psychiatry Res. Mar. 22. 1999;85(3):263-73. [pmid: 10333379].
227 Cooper AJ, Finlayson R, Velamoor VR, Magnus RV, Cernovsky Z. Effects of ECT on prolactin, LH, FSH and testosterone in males with major depressive illness. Can J Psychiatry. Nov. 1989;34(8):814-7. [pmid: 2510920].
228 Copeland JR. Depressive illness and morbid distress. Onset and development data examined against five-year outcome. Br J Psychiatry. Mar. 1985;146:297-307. [pmid: 3986440].
229 Coplan JD, Tiffon L, Gorman JM. Therapeutic strategies for the patient with treatment-resistant anxiety. J Clin Psychiatry. May. Suppl. 1993;54:69-74. [pmid: 8509358].
230 Coppen A. Depression as a lethal disease: prevention strategies. J Clin Psychiatry. Apr. Suppl. 1994;55:37-45. [pmid: 8077174].
231 Coppen A. Lithium in unipolar depression and the prevention of suicide. J Clin Psychiatry. 9. 2000;61:52-6. [pmid: 10826662].
232 Coppen A, Abou-Saleh MT, Milln P, Bailey J, Metcalfe M, Burns BH, et al. Lithium continuation therapy following electroconvulsive therapy. Br J Psychiatry. Oct. 1981;139:284-7. [pmid: 6799032].
233 Corcoran C, Connor TJ, O'Keane V, Garland MR. The effects of vagus nerve stimulation on pro- and anti-inflammatory cytokines in humans: a preliminary report. Neuroimmunomodulation. 2005;12(5):307-9. [pmid: 16166810].
234 Corcoran CD, Thomas P, Phillips J, O'Keane V. Vagus nerve stimulation in chronic treatment-resistant depression: preliminary findings of an open-label study. Br J Psychiatry. Sep. 2006;189:282-3. [pmid: 16946367].
235 Corey-Lisle PK, Birnbaum HG, Greenberg PE, Marynchenko MB, Claxton AJ. Identification of a claims data “signature” and economic consequences for treatment-resistant depression. J Clin Psychiatry. Aug. 2002;63(8):717-26. [pmid: 12197453].
236 Corya SA, Andersen SW, Detke HC, Kelly LS, Van Campen LE, Sanger TM, et al. Long-term antidepressant efficacy and safety of olanzapine/fluoxetine combination: a 76-week open-label study. J Clin Psychiatry. Nov. 2003;64(11):1349-56. [pmid: 14658950].
237 Corya SA, Williamson D, Sanger TM, Briggs SD, Case M, Tollefson G. A randomized, double-blind comparison of olanzapine/fluoxetine combination, olanzapine, fluoxetine, and venlafaxine in treatment-resistant depression. Depress Anxiety. 2006:364-72.
238 Coryell W, Endicott J, Keller M. Outcome of patients with chronic affective disorder: a five-year follow-up. Am J Psychiatry. Dec. 1990;147(12):1627-33. [pmid: 2244640].
239 Coryell W, Noyes R, Clancy J. Panic disorder and primary unipolar depression. A comparison of background and outcome. J Affect Disord. Nov. 1983;5(4):311-7. [pmid: 6229563].
240 Coryell W, Tsuang MT. Primary unipolar depression and the prognostic importance of delusions. Arch Gen Psychiatry. Oct. 1982;39(10):1181-4. [pmid: 7125847].
241 Coryell W, Zimmerman M. Outcome following ECT for primary unipolar depression: a test of newly proposed response predictors. Am J Psychiatry. Jul. 1984;141(7):862-7. [pmid: 6731634].
242 Cowen PJ. Depression resistant to tricyclic antidepressants. Bmj. Aug. 13. 1988;297(6646):435-6. [pmid: 3139133].
243 Cowen PJ. Commentary on STAR*D: a summary and UK perspective. J Psychopharmacol. Aug. 2009;23(6):618-9. discussion 22-4. [pmid: 19395431].
244 Cowen PJ, McCance SL, Cohen PR, Julier DL. Lithium increases 5-HT-mediated neuroendocrine responses in tricyclic resistant depression. Psychopharmacology (Berl). 1989;99(2):230-2. [pmid: 2508159].
245 Cowen PJ, McCance SL, Ware CJ, Cohen PR, Chalmers JS, Julier DL. Lithium in tricyclic-resistant depression. Correlation of increased brain 5-HT function with clinical outcome. Br J Psychiatry. Sep. 1991;159:341-6. [pmid: 1659918].
246 Craig TJ, Grossman S, Bromet EJ, Fochtmann LJ, Carlson GA. Medication use patterns and two-year outcome in first-admission patients with major depressive disorder with psychotic features. Compr Psychiatry. Nov-Dec. 2007;48(6):497-503. [pmid: 17954133].
247 Crebbin K, Mitford E, Paxton R, Turkington D. First-episode psychosis: an epidemiological survey comparing psychotic depression with schizophrenia. J Affect Disord. Jan. 2008;105(1-3):117-24. [pmid: 17574683].
248 Crevits L, Van den Abbeele D, Audenaert K, Goethals M, Dierick M. Effect of repetitive transcranial magnetic stimulation on saccades in depression: a pilot study. Psychiatry Res. Jun. 15. 2005;135(2):113-9. [pmid: 15919118].
249 Criado JM, Fernandez A, Ortiz T. Long-term effects of electroconvulsive therapy on episodic memory. Actas Esp Psiquiatr. Jan-Feb. 2007;35(1):40-6. [pmid: 17323224].
250 Cronholm B, Ottosson JO. Experimental studies of the therapeutic action of electroconvulsive therapy in endogenous depression. The role of the electrical stimulation and of the seizure studied by variation of stimulus intensity and modification by lidocaine of seizure discharge. Convuls Ther. Sep. 1996;12(3):172-94. [pmid: 8872406].
251 Crossley NA, Bauer M. Acceleration and augmentation of antidepressants with lithium for depressive disorders: two meta-analyses of randomized, placebo-controlled trials. J Clin Psychiatry. Jun. 2007;68(6):935-40. [pmid: 17592920].
252 Croughan JL, Secunda SK, Katz MM, Robins E, Mendels J, Swann A, et al. Sociodemographic and prior clinical course characteristics associated with treatment response in depressed patients. J Psychiatr Res. 1988;22(3):227-37. [pmid: 3066896].
253 Crow TJ, Johnstone EC. Controlled trials of electroconvulsive therapy. Ann N Y Acad Sci. 1986;462:12-29. [pmid: 2871792].
254 Croxtall JD, Scott LJ. Olanzapine/fluoxetine: a review of its use in patients with treatment-resistant major depressive disorder. CNS Drugs. Mar. 1. 2010;24(3):245-62. [pmid: 20155998].
255 Cullen M, Mitchell P, Brodaty H, Boyce P, Parker G, Hickie I, et al. Carbamazepine for treatment-resistant melancholia. J Clin Psychiatry. Nov. 1991;52(11):472-6. [pmid: 1744065].
256 Culpepper L. Why do you need to move beyond first-line therapy for major depression?. J Clin Psychiatry. 1. 2010;71:4-9. [pmid: 20977873].
257 Curran S. Effect of paroxetine on seizure length during electroconvulsive therapy. Acta Psychiatr Scand. Sep. 1995;92(3):239-40. [pmid: 7484206].
258 Currier MB, Murray GB, Welch CC. Electroconvulsive therapy for post-stroke depressed geriatric patients. J Neuropsychiatry Clin Neurosci. Spring. 1992;4(2):140-4. [pmid: 1627974].
259 Dailly E, Chenu F, Renard CE, Bourin M. Dopamine, depression and antidepressants. Fundam Clin Pharmacol. Dec. 2004;18(6):601-7. [pmid: 15548230].
260 Dallal A, Fontaine R, Ontiveros A, Elie R. Lithium carbonate augmentation of desipramine in refractory depression. Can J Psychiatry. Oct. 1990;35(7):608-11. [pmid: 2125237].
261 Dalton EJ, Rotondi D, Levitan RD, Kennedy SH, Brown GM. Use of slow-release melatonin in treatment-resistant depression. J Psychiatry Neurosci. Jan. 2000;25(1):48-52. [pmid: 10721684].
262 Daly RJ, Duggan PF, Bracken PJ, Doonan HJ, Kelleher NJ. Plasma levels of beta-endorphin in depressed patients with and without pain. Br J Psychiatry. Feb. 1987;150:224-7. [pmid: 2958101].
263 Dang T, Avery DH, Russo J. Within-session mood changes from TMS in depressed patients. J Neuropsychiatry Clin Neurosci. Fall. 2007;19(4):458-63. [pmid: 18070851].
264 Daniel WF, Crovitz HF, Weiner RD. Perceptual learning with right unilateral versus bilateral electroconvulsive therapy. Br J Psychiatry. Oct. 1984;145:394-400. [pmid: 6487913].
265 Dannon PN, Dolberg OT, Schreiber S, Grunhaus L. Three and six-month outcome following courses of either ECT or rTMS in a population of severely depressed individuals--preliminary report. Biol Psychiatry. Apr. 15. 2002;51(8):687-90. [pmid: 11955470].
266 DasGupta K. Treatment of depression in elderly patients: recent advances. Arch Fam Med. May-Jun. 1998;7(3):274-80. [pmid: 9596464].
267 Davidson JR. First-line pharmacotherapy approaches for generalized anxiety disorder. J Clin Psychiatry. 2. 2009;70:25-31. [pmid: 19371504].
268 Dawson R, Lavori PW, Coryell WH, Endicott J, Keller MB. Course of treatment received by depressed patients. J Psychiatr Res. May-Jun. 1999;33(3):233-42. [pmid: 10367989].
269 De Fruyt F, Van Leeuwen K, Bagby RM, Rolland JP, Rouillon F. Assessing and interpreting personality change and continuity in patients treated for major depression. Psychol Assess. Mar. 2006;18(1):71-80. [pmid: 16594814].
270 de Groot MH, Nolen WA, Huijsman AM, Bouvy PF. Lateralized neuropsychological functioning in depressive patients before and after drug therapy. Biol Psychiatry. Dec. 15. 1996;40(12):1282-7. [pmid: 8959293].
271 De Montigny C. Enhancement of the 5-HT neurotransmission by antidepressant treatments. J Physiol (Paris). 1981;77(2-3):455-61. [pmid: 6270317].
272 de Montigny C. Lithium addition in treatment-resistant depression. Int Clin Psychopharmacol. Jun. 2. 1994;9:31-5. [pmid: 7930494].
273 de Montigny C, Cournoyer G, Morissette R, Langlois R, Caille G. Lithium carbonate addition in tricyclic antidepressant-resistant unipolar depression. Correlations with the neurobiologic actions of tricyclic antidepressant drugs and lithium ion on the serotonin system. Arch Gen Psychiatry. Dec. 1983;40(12):1327-34. [pmid: 6418109].
274 De Montigny C, Grunberg F, Mayer A, Deschenes JP. Lithium induces rapid relief of depression in tricyclic antidepressant drug non-responders. Br J Psychiatry. Mar. 1981;138:252-6. [pmid: 7272619].
275 de Vreede IM, Burger H, van Vliet IM. Prediction of response to ECT with routinely collected data in major depression. J Affect Disord. Jun. 2005;86(2-3):323-7. [pmid: 15935255].
276 DeBattista C. Augmentation and combination strategies for depression. J Psychopharmacol. May. 2006;20(3 Suppl):11-8. [pmid: 16644767].
277 DeBattista C, DeBattista K. Safety considerations of the use of second generation antipsychotics in the treatment of major depression: extrapyramidal and metabolic side effects. Curr Drug Saf. Jul. 2. 2010;5(3):263-6. [pmid: 20394571].
278 DeBattista C, Hawkins J. Utility of atypical antipsychotics in the treatment of resistant unipolar depression. CNS Drugs. 2009;23(5):369-77. [pmid: 19453199].
279 DeBattista C, Lembke A. Update on augmentation of antidepressant response in resistant depression. Curr Psychiatry Rep. Dec. 2005;7(6):435-40. [pmid: 16318821].
280 DeBattista C, Solvason HB, Poirier J, Kendrick E, Schatzberg AF. A prospective trial of bupropion SR augmentation of partial and non-responders to serotonergic antidepressants. J Clin Psychopharmacol. Feb. 2003;23(1):27-30. [pmid: 12544372].
281 Dechant KL, Clissold SP. Paroxetine. A review of its pharmacodynamic and pharmacokinetic properties, and therapeutic potential in depressive illness. Drugs. Feb. 1991;41(2):225-53. [pmid: 1709852].
282 Defrin R, Grunhaus L, Zamir D, Zeilig G. The effect of a series of repetitive transcranial magnetic stimulations of the motor cortex on central pain after spinal cord injury. Arch Phys Med Rehabil. Dec. 2007;88(12):1574-80. [pmid: 18047871].
283 Delgado PL, Price LH, Charney DS, Heninger GR. Efficacy of fluvoxamine in treatment-refractory depression. J Affect Disord. Jul-Aug. 1988;15(1):55-60. [pmid: 2970493].
284 Delgado PL, Price LH, Miller HL, Salomon RM, Aghajanian GK, Heninger GR, et al. Serotonin and the neurobiology of depression. Effects of tryptophan depletion in drug-free depressed patients. Arch Gen Psychiatry. Nov. 1994;51(11):865-74. [pmid: 7944875].
285 d'Elia G, Frederiksen SO. ACTH4-10 and memory in ECT-treated patients and untreated controls. II. Effect on retrieval. Acta Psychiatr Scand. Nov. 1980;62(5):429-35. [pmid: 6259886].
286 d'Elia G, Frederiksen SO. ACTH4-10 and memory in ECT-treated and untreated patients. I. Effect on consolidation. Acta Psychiatr Scand. Nov. 1980;62(5):418-28. [pmid: 6259885].
287 Delva NJ, Brunet DG, Hawken ER, Kesteven RM, Lawson JS, Lywood DW, et al. Characteristics of responders and nonresponders to brief-pulse right unilateral ECT in a controlled clinical trial. J Ect. Jun. 2001;17(2):118-23. [pmid: 11417922].
288 DeMet EM, Bell KM, Reist C, Gerner RH, Chicz-DeMet A. Seasonal changes in cyanoimipramine specific platelet 3H-imipramine binding in depression. Psychiatry Res. Dec. 1990;34(3):315-29. [pmid: 1963694].
289 DeMet EM, Chicz-DeMet A. Subclasses of platelet 3H-imipramine binding sites. Psychiatry Res. Dec. 1990;34(3):293-302. [pmid: 1963692].
290 Demirtas-Tatlidede A, Mechanic-Hamilton D, Press DZ, Pearlman C, Stern WM, Thall M, et al. An open-label, prospective study of repetitive transcranial magnetic stimulation (rTMS) in the long-term treatment of refractory depression: reproducibility and duration of the antidepressant effect in medication-free patients. J Clin Psychiatry. Jun. 2008;69(6):930-4. [pmid: 18505308].
291 Dessauer M, Goetze U, Tolle R. Periodic sleep deprivation in drug-refractory depression. Neuropsychobiology. 1985;13(3):111-6. [pmid: 3900797].
292 Devanand DP, Dwork AJ, Hutchinson ER, Bolwig TG, Sackeim HA. Does ECT alter brain structure?. Am J Psychiatry. Jul. 1994;151(7):957-70. [pmid: 8010381].
293 Devanand DP, Fitzsimons L, Prudic J, Sackeim HA. Subjective side effects during electroconvulsive therapy. Convuls Ther. Dec. 1995;11(4):232-40. [pmid: 8919573].
294 Devanand DP, Lisanby S, Lo ES, Fitzsimons L, Cooper TB, Halbreich U, et al. Effects of electroconvulsive therapy on plasma vasopressin and oxytocin. Biol Psychiatry. Oct. 1. 1998;44(7):610-6. [pmid: 9787885].
295 Devanand DP, Sackeim HA, Prudic J. Electroconvulsive therapy in the treatment-resistant patient. Psychiatr Clin North Am. Dec. 1991;14(4):905-23. [pmid: 1771153].
296 Devanand DP, Verma AK, Tirumalasetti F, Sackeim HA. Absence of cognitive impairment after more than 100 lifetime ECT treatments. Am J Psychiatry. Jul. 1991;148(7):929-32. [pmid: 2053635].
297 Dew R, McCall WV. Efficiency of outpatient ECT. J Ect. Mar. 2004;20(1):24-5. [pmid: 15087993].
298 Dick PH, Sweeney ML, Crombie IK. Controlled comparison of day-patient and out-patient treatment for persistent anxiety and depression. Br J Psychiatry. Jan. 1991;158:24-7. [pmid: 2015447].
299 Dietrich DE, Emrich HM. The use of anticonvulsants to augment antidepressant medication. J Clin Psychiatry. 5. 1998;59:51-8. discussion 9. [pmid: 9635548].
300 Dinan TG. Lithium augmentation in sertraline-resistant depression: a preliminary dose-response study. Acta Psychiatr Scand. Oct. 1993;88(4):300-1. [pmid: 8256650].
301 Dinan TG, Barry S. A comparison of electroconvulsive therapy with a combined lithium and tricyclic combination among depressed tricyclic nonresponders. Acta Psychiatr Scand. Jul. 1989;80(1):97-100. [pmid: 2504034].
302 Dinan TG, Lavelle E, Cooney J, Burnett F, Scott L, Dash A, et al. Dexamethasone augmentation in treatment-resistant depression. Acta Psychiatr Scand. Jan. 1997;95(1):58-61. [pmid: 9051162].
303 Dinan TG, Mobayed M. Treatment resistance of depression after head injury: a preliminary study of amitriptyline response. Acta Psychiatr Scand. Apr. 1992;85(4):292-4. [pmid: 1595364].
304 Dodd S, Berk M. Olanzapine/fluoxetine combination for treatment-resistant depression: efficacy and clinical utility. Expert Rev Neurother. Sep. 2008;8(9):1299-306. [pmid: 18759541].
305 Dodd S, Horgan D, Malhi GS, Berk M. To combine or not to combine? A literature review of antidepressant combination therapy. J Affect Disord. Dec. 2005;89(1-3):1-11. [pmid: 16169088].
306 Dombrovski AY, Mulsant BH, Haskett RF, Prudic J, Begley AE, Sackeim HA. Predictors of remission after electroconvulsive therapy in unipolar major depression. J Clin Psychiatry. Aug. 2005;66(8):1043-9. [pmid: 16086621].
307 Dording CM. Antidepressant augmentation and combinations. Psychiatr Clin North Am. Dec. 2000;23(4):743-55. [pmid: 11147245].
308 Doree JP, Des Rosiers J, Lew V, Gendron A, Elie R, Stip E, et al. Quetiapine augmentation of treatment-resistant depression: a comparison with lithium. Curr Med Res Opin. Feb. 2007;23(2):333-41. [pmid: 17288688].
309 Dowson JH. MAO inhibitors in mental disease: their current status. J Neural Transm Suppl. 1987;23:121-38. [pmid: 3295114].
310 Dragasevic N, Potrebic A, Damjanovic A, Stefanova E, Kostic VS. Therapeutic efficacy of bilateral prefrontal slow repetitive transcranial magnetic stimulation in depressed patients with Parkinson's disease: an open study. Mov Disord. May. 2002;17(3):528-32. [pmid: 12112202].
311 Dratcu L, Calil HM. The dexamethasone suppression test: its relationship to diagnoses, severity of depression and response to treatment. Prog Neuropsychopharmacol Biol Psychiatry. 1989;13(1-2):99-117. [pmid: 2748868].
312 Dubovsky SL, Buzan R, Thomas M, Kassner C, Cullum CM. Nicardipine improves the antidepressant action of ECT but does not improve cognition. J Ect. Mar. 2001;17(1):3-10. [pmid: 11281512].
313 Dubovsky SL, Christiano J, Daniell LC, Franks RD, Murphy J, Adler L, et al. Increased platelet intracellular calcium concentration in patients with bipolar affective disorders. Arch Gen Psychiatry. Jul. 1989;46(7):632-8. [pmid: 2735813].
314 Dubovsky SL, Thomas M. Psychotic depression: advances in conceptualization and treatment. Hosp Community Psychiatry. Dec. 1992;43(12):1189-98. [pmid: 1360938].
315 Dudley DL, Volberding N, Loebel P. Intravenous chlorimipramine and refractory depression. Gen Hosp Psychiatry. Mar. 1980;2(1):61-4. [pmid: 7380252].
316 Dunner DL. Therapeutic considerations in treating depression in the elderly. J Clin Psychiatry. Dec. Suppl. 1994;55:48-58. discussion 9-60. [pmid: 7814358].
317 Dunner DL, Amsterdam JD, Shelton RC, Loebel A, Romano SJ. Efficacy and tolerability of adjunctive ziprasidone in treatment-resistant depression: a randomized, open-label, pilot study. J Clin Psychiatry. Jul. 2007;68(7):1071-7. [pmid: 17685744].
318 Dursun SM, Devarajan S, Kutcher S. The ‘dalhousie serotonin cocktail’ for treatment-resistant major depressive disorder. J Psychopharmacol. Jun. 2001;15(2):136-8. [pmid: 11448087].
319 Dursun SM, Patel JK, Drybala T, Shinkwin R, Drybala G, Reveley MA. Effects of antidepressant treatments on first-ECT seizure duration in depression. Prog Neuropsychopharmacol Biol Psychiatry. Feb. 2001;25(2):437-43. [pmid: 11294487].
320 Dziedzicka-Wasylewska M, Rogoz Z, Solich J, Dudek D, Wrobel A, Zieba A. Effect of joint administration of imipramine and amantadine on binding of [3H]7-OH-DPAT to dopamine D3 receptors in peripheral blood lymphocytes of the patients with drug-resistant unipolar depression. Pol J Pharmacol. Nov-Dec. 2002;54(6):703-6. [pmid: 12866728].
321 Ebert D, Albert R, May A, Stosiek I, Kaschka W. Combined SSRI-RIMA treatment in refractory depression. Safety data and efficacy. Psychopharmacology (Berl). Jun. 1995;119(3):342-4. [pmid: 7675971].
322 Eby GA 3rd, Eby KL. Magnesium for treatment-resistant depression: a review and hypothesis. Med Hypotheses. Apr. 2010;74(4):649-60. [pmid: 19944540].
323 Egberts AC, Lenderink AW, de Koning FH, Leufkens HG. Channeling of three newly introduced antidepressants to patients not responding satisfactorily to previous treatment. J Clin Psychopharmacol. Jun. 1997;17(3):149-55. [pmid: 9169957].
324 Eggar R, Spencer A, Anderson D, Hiller L. Views of elderly patients on cardiopulmonary resuscitation before and after treatment for depression. Int J Geriatr Psychiatry. Feb. 2002;17(2):170-4. [pmid: 11813281].
325 Ehnvall A, Sjogren M, Zachrisson OC, Agren H. Lifetime burden of mood swings and activation of brain norepinephrine turnover in patients with treatment-refractory depressive illness. J Affect Disord. Apr. 2003;74(2):185-9. [pmid: 12706520].
326 Eichhammer P, Kharraz A, Wiegand R, Langguth B, Frick U, Aigner JM, et al. Sleep deprivation in depression stabilizing antidepressant effects by repetitive transcranial magnetic stimulation. Life Sci. Mar. 1. 2002;70(15):1741-9. [pmid: 12002519].
327 El Khoury A, Johnson L, Aberg-Wistedt A, Stain-Malmgren R. Effects of long-term lithium treatment on monoaminergic functions in major depression. Psychiatry Res. Dec. 15. 2001;105(1-2):33-44. [pmid: 11740973].
328 El Mansari M, Guiard BP, Chernoloz O, Ghanbari R, Katz N, Blier P. Relevance of norepinephrine-dopamine interactions in the treatment of major depressive disorder. CNS Neurosci Ther. Jun. 2010;16(3):e1-17. [pmid: 20406250].
329 Elger G, Hoppe C, Falkai P, Rush AJ, Elger CE. Vagus nerve stimulation is associated with mood improvements in epilepsy patients. Epilepsy Res. Dec. 2000;42(2-3):203-10. [pmid: 11074193].
330 Elliott RL. Depression in primary care. Ethn Dis. Spring. 2007;17(2 Suppl 2):S2-28. 33. [pmid: 17684811].
331 Engelhardt W, Carl G, Hartung E. Intra-individual open comparison of burst-suppression-isoflurane-anaesthesia versus electroconvulsive therapy in the treatment of severe depression. Eur J Anaesthesiol. Mar. 1993;10(2):113-8. [pmid: 8462536].
332 Eranti SV, Mogg AJ, Pluck GC, Landau S, McLoughlin DM. Methohexitone, propofol and etomidate in electroconvulsive therapy for depression: a naturalistic comparison study. J Affect Disord. Feb. 2009;113(1-2):165-71. [pmid: 18439686].
333 Erinosho OA, Ayonrinde A. A cross-national comparison of patterns of utilization and psychiatric care. Int J Soc Psychiatry. Winter. 1981;27(4):289-96. [pmid: 7327879].
334 Eschweiler GW, Vonthein R, Bode R, Huell M, Conca A, Peters O, et al. Clinical efficacy and cognitive side effects of bifrontal versus right unilateral electroconvulsive therapy (ECT): a short-term randomised controlled trial in pharmaco-resistant major depression. J Affect Disord. Aug. 2007;101(1-3):149-57. [pmid: 17196664].
335 Ezzat DH, Ibraheem MM, Makhawy B. The effect of Piracetam on ECT--induced memory disturbances. Br J Psychiatry. Dec. 1985;147:720-1. [pmid: 3913489].
336 Fava GA. Can long-term treatment with antidepressant drugs worsen the course of depression?. J Clin Psychiatry. Feb. 2003;64(2):123-33. [pmid: 12633120].
337 Fava GA, Park SK, Sonino N. Treatment of recurrent depression. Expert Rev Neurother. Nov. 2006;6(11):1735-40. [pmid: 17144786].
338 Fava GA, Savron G, Grandi S, Rafanelli C. Cognitive-behavioral management of drug-resistant major depressive disorder. J Clin Psychiatry. Jun. 1997;58(6):278-82. quiz 83-4. [pmid: 9228899].
339 Fava M. New approaches to the treatment of refractory depression. J Clin Psychiatry. 1. 2000;61:26-32. [pmid: 10703760].
340 Fava M. Augmentation and combination strategies in treatment-resistant depression. J Clin Psychiatry. 18. 2001;62:4-11. [pmid: 11575733].
341 Fava M. Diagnosis and definition of treatment-resistant depression. Biol Psychiatry. Apr. 15. 2003;53(8):649-59. [pmid: 12706951].
342 Fava M. Augmentation and combination strategies for complicated depression. J Clin Psychiatry. Nov. 2009;70(11):e40. [pmid: 20031088].
343 Fava M. Partial responders to antidepressant treatment: switching strategies. J Clin Psychiatry. Jul. 2009;70(7):e24. [pmid: 19653970].
344 Fava M. Switching treatments for complicated depression. J Clin Psychiatry. Feb. 2010;71(2):e04. [pmid: 20193643].
345 Fava M, Davidson KG. Definition and epidemiology of treatment-resistant depression. Psychiatr Clin North Am. Jun. 1996;19(2):179-200. [pmid: 8827185].
346 Fava M, Papakostas GI, Petersen T, Mahal Y, Quitkin F, Stewart J, et al. Switching to bupropion in fluoxetine-resistant major depressive disorder. Ann Clin Psychiatry. Mar. 2003;15(1):17-22. [pmid: 12839429].
347 Fava M, Rosenbaum JF, McGrath PJ, Stewart JW, Amsterdam JD, Quitkin FM. Lithium and tricyclic augmentation of fluoxetine treatment for resistant major depression: a double-blind, controlled study. Am J Psychiatry. Sep. 1994;151(9):1372-4. [pmid: 8067495].
348 Fava M, Rush AJ, Wisniewski SR, Nierenberg AA, Alpert JE, McGrath PJ, et al. A comparison of mirtazapine and nortriptyline following two consecutive failed medication treatments for depressed outpatients: a STAR*D report. Am J Psychiatry. 2006:1161-72.
349 Fawcett J. Compliance: definitions and key issues. J Clin Psychiatry. 1. 1995;56:4-8. discussion 9-10. [pmid: 7836349].
350 Fawcett JA. Lithium combinations in acute and maintenance treatment of unipolar and bipolar depression. J Clin Psychiatry. 5. 2003;64:32-7. [pmid: 12720482].
351 Feighner JP. The role of venlafaxine in rational antidepressant therapy. J Clin Psychiatry. Sep. A. 1994;55:62-8. discussion 9-70, 98-100. [pmid: 7961545].
352 Feighner JP, Boyer WF, Tyler DL, Neborsky RJ. Adverse consequences of fluoxetine-MAOI combination therapy. J Clin Psychiatry. Jun. 1990;51(6):222-5. [pmid: 2347858].
353 Feighner JP, Sverdlov L, Hlavka J, Nicolau G, Cartwright K, Freed JS. Clinical effect of nemifitide, a novel pentapeptide antidepressant, in the treatment of severely depressed refractory patients. Int Clin Psychopharmacol. Jan. 2008;23(1):29-35. [pmid: 18090505].
354 Fekadu A, Wooderson S, Donaldson C, Markopoulou K, Masterson B, Poon L, et al. A multidimensional tool to quantify treatment resistance in depression: the Maudsley staging method. J Clin Psychiatry. Feb. 2009;70(2):177-84. [pmid: 19192471].
355 Fekadu A, Wooderson SC, Markopoulo K, Donaldson C, Papadopoulos A, Cleare AJ. What happens to patients with treatment-resistant depression? A systematic review of medium to long term outcome studies. J Affect Disord. Jul. 2009;116(1-2):4-11. [pmid: 19007996].
356 Fekadu A, Wooderson SC, Markopoulou K, Cleare AJ. The Maudsley Staging Method for treatment-resistant depression: prediction of longer-term outcome and persistence of symptoms. J Clin Psychiatry. Jul. 2009;70(7):952-7. [pmid: 19457299].
357 Feske U, Mulsant BH, Pilkonis PA, Soloff P, Dolata D, Sackeim HA, et al. Clinical outcome of ECT in patients with major depression and comorbid borderline personality disorder. Am J Psychiatry. Nov. 2004;161(11):2073-80. [pmid: 15514409].
358 Figiel GS, Coffey CE, Djang WT, Hoffman G Jr, Doraiswamy PM. Brain magnetic resonance imaging findings in ECT-induced delirium. J Neuropsychiatry Clin Neurosci. Winter. 1990;2(1):53-8. [pmid: 2136061].
359 Figiel GS, DeLeo B, Zorumski CF, Baker K, Goewert A, Jarvis M, et al. Combined use of labetalol and nifedipine in controlling the cardiovascular response from ECT. J Geriatr Psychiatry Neurol. Jan-Mar. 1993;6(1):20-4. [pmid: 8422266].
360 Fink M, Rush AJ, Knapp R, Rasmussen K, Mueller M, Rummans TA, et al. DSM melancholic features are unreliable predictors of ECT response: a CORE publication. J Ect. Sep. 2007;23(3):139-46. [pmid: 17804986].
361 Fitzgerald P. Is it time to introduce repetitive transcranial magnetic stimulation into standard clinical practice for the treatment of depressive disorders. Aust N Z J Psychiatry. Feb. 2003;37(1):5-11. discussion 2-4. [pmid: 12534650].
362 Fitzgerald P, O'Brien SM, Scully P, Rijkers K, Scott LV, Dinan TG. Cutaneous glucocorticoid receptor sensitivity and pro-inflammatory cytokine levels in antidepressant-resistant depression. Psychol Med. Jan. 2006;36(1):37-43. [pmid: 16255837].
363 Fitzgerald PB, Benitez J, de Castella A, Daskalakis ZJ, Brown TL, Kulkarni J. A randomized, controlled trial of sequential bilateral repetitive transcranial magnetic stimulation for treatment-resistant depression. Am J Psychiatry. Jan. 2006;163(1):88-94. [pmid: 16390894].
364 Fitzgerald PB, Brown TL, Marston NA, Daskalakis ZJ, De Castella A, Kulkarni J. Transcranial magnetic stimulation in the treatment of depression: a double-blind, placebo-controlled trial. Arch Gen Psychiatry. Oct. 2003;60(10):1002-8. [pmid: 14557145].
365 Fitzgerald PB, Hoy K, McQueen S, Herring S, Segrave R, Been G, et al. Priming stimulation enhances the effectiveness of low-frequency right prefrontal cortex transcranial magnetic stimulation in major depression. J Clin Psychopharmacol. Feb. 2008;28(1):52-8. [pmid: 18204341].
366 Fitzgerald PB, Hoy K, McQueen S, Maller JJ, Herring S, Segrave R, et al. A randomized trial of rTMS targeted with MRI based neuro-navigation in treatment-resistant depression. Neuropsychopharmacology. Apr. 2009;34(5):1255-62. [pmid: 19145228].
367 Fitzgerald PB, Huntsman S, Gunewardene R, Kulkarni J, Daskalakis ZJ. A randomized trial of low-frequency right-prefrontal-cortex transcranial magnetic stimulation as augmentation in treatment-resistant major depression. Int J Neuropsychopharmacol. Dec. 2006;9(6):655-66. [pmid: 16959055].
368 Fitzgerald PB, McQueen S, Herring S, Hoy K, Segrave R, Kulkarni J, et al. A study of the effectiveness of high-frequency left prefrontal cortex transcranial magnetic stimulation in major depression in patients who have not responded to right-sided stimulation. Psychiatry Res. Aug. 30. 2009;169(1):12-5. [pmid: 19631391].
369 Fitzgerald PB, Sritharan A, Daskalakis ZJ, de Castella AR, Kulkarni J, Egan G. A functional magnetic resonance imaging study of the effects of low frequency right prefrontal transcranial magnetic stimulation in depression. J Clin Psychopharmacol. Oct. 2007;27(5):488-92. [pmid: 17873682].
370 Fleck MP, Horwath E. Pharmacologic management of difficult-to-treat depression in clinical practice. Psychiatr Serv. Aug. 2005;56(8):1005-11. [pmid: 16088019].
371 Flint AJ, Rifat SL. A prospective study of lithium augmentation in antidepressant-resistant geriatric depression. J Clin Psychopharmacol. Oct. 1994;14(5):353-6. [pmid: 7806693].
372 Flint AJ, Rifat SL. The effect of sequential antidepressant treatment on geriatric depression. J Affect Disord. Jan. 22. 1996;36(3-4):95-105. [pmid: 8821312].
373 Flint AJ, Rifat SL. Anxious depression in elderly patients. Response to antidepressant treatment. Am J Geriatr Psychiatry. Spring. 1997;5(2):107-15. [pmid: 9106374].
374 Flint AJ, Rifat SL. Effect of demographic and clinical variables on time to antidepressant response in geriatric depression. Depress Anxiety. 1997;5(2):103-7. [pmid: 9262941].
375 Flint AJ, Rifat SL. The treatment of psychotic depression in later life: a comparison of pharmacotherapy and ECT. Int J Geriatr Psychiatry. Jan. 1998;13(1):23-8. [pmid: 9489577].
376 Flint AJ, Rifat SL. Two-year outcome of psychotic depression in late life. Am J Psychiatry. Feb. 1998;155(2):178-83. [pmid: 9464195].
377 Flint AJ, Rifat SL. Maintenance treatment for recurrent depression in late life. A four-year outcome study. Am J Geriatr Psychiatry. Spring. 2000;8(2):112-6. [pmid: 10804071].
378 Flint AJ, Rifat SL. Nonresponse to first-line pharmacotherapy may predict relapse and recurrence of remitted geriatric depression. Depress Anxiety. 2001;13(3):125-31. [pmid: 11387732].
379 Folkerts HW, Michael N, Tölle R, Schonauer K, Mucke S, Schulze-Monking H. Electroconvulsive therapy vs. paroxetine in treatment-resistant depression -- a randomized study. Acta Psychiatr Scand. Nov. 1997;96(5):334-42. [pmid: 9395150].
380 Fontaine R, Ontiveros A, Elie R, Vezina M. Lithium carbonate augmentation of desipramine and fluoxetine in refractory depression. Biol Psychiatry. May. 1. 1991;29(9):946-8. [pmid: 1904782].
381 Fontaine R, Young T. Unilateral ECT: advantages and efficacy in the treatment of depression. Can J Psychiatry. Mar. 1985;30(2):142-7. [pmid: 3995457].
382 Fountoulakis KN, Kantartzis S, Siamouli M, Panagiotidis P, Kaprinis S, Iacovides A, et al. Peripheral thyroid dysfunction in depression. World J Biol Psychiatry. 2006;7(3):131-7. [pmid: 16861138].
383 Franco-Bronson K. The management of treatment-resistant depression in the medically ill. Psychiatr Clin North Am. Jun. 1996;19(2):329-50. [pmid: 8827193].
384 Frasca TA, Iodice A, McCall WV. The relationship between changes in learning and memory after right unilateral electroconvulsive therapy. J Ect. Sep. 2003;19(3):148-50. [pmid: 12972984].
385 Fraser RM, Glass IB. Unilateral and bilateral ECT in elderly patients. A comparative study. Acta Psychiatr Scand. Jul. 1980;62(1):13-31. [pmid: 7446190].
386 Frederiksen SO, d'Elia G, Holsten F. Influence of ACTH 4-10 and unilateral ECT on primary and secondary memory in depressive patients. Eur Arch Psychiatry Neurol Sci. 1985;234(5):291-4. [pmid: 2985395].
387 Fredman B, d'Etienne J, Smith I, Husain MM, White PF. Anesthesia for electroconvulsive therapy: effects of propofol and methohexital on seizure activity and recovery. Anesth Analg. Jul. 1994;79(1):75-9. [pmid: 8010457].
388 Fredman SJ, Rosenbaum JF. Recurrent depression, resistant clinician. Harv Rev Psychiatry. Jan-Feb. 1998;5(5):281-5. [pmid: 9493950].
389 Freeman CP, Weeks D, Kendell RE. ECT: II: patients who complain. Br J Psychiatry. Jul. 1980;137:17-25. [pmid: 7459536].
390 Fregni F, Marcolin MA, Myczkowski M, Amiaz R, Hasey G, Rumi DO, et al. Predictors of antidepressant response in clinical trials of transcranial magnetic stimulation. Int J Neuropsychopharmacol. Dec. 2006;9(6):641-54. [pmid: 16939662].
391 Fregni F, Ono CR, Santos CM, Bermpohl F, Buchpiguel C, Barbosa ER, et al. Effects of antidepressant treatment with rTMS and fluoxetine on brain perfusion in PD. Neurology. Jun. 13. 2006;66(11):1629-37. [pmid: 16769932].
392 Fregni F, Santos CM, Myczkowski ML, Rigolino R, Gallucci-Neto J, Barbosa ER, et al. Repetitive transcranial magnetic stimulation is as effective as fluoxetine in the treatment of depression in patients with Parkinson's disease. J Neurol Neurosurg Psychiatry. Aug. 2004;75(8):1171-4. [pmid: 15258224].
393 Frith CD, Stevens M, Johnstone EC, Deakin JF, Lawler P, Crow TJ. Effects of ECT and depression on various aspects of memory. Br J Psychiatry. 1983:610-7.
394 Frith CD, Stevens M, Johnstone EC, Deakin JF, Lawler P, Crow TJ. A comparison of some retrograde and anterograde effects of electroconvulsive shock in patients with severe depression. Br J Psychol. 1987:53-63.
395 Frye MA, Ketter TA, Leverich GS, Huggins T, Lantz C, Denicoff KD, et al. The increasing use of polypharmacotherapy for refractory mood disorders: 22 years of study. J Clin Psychiatry. Jan. 2000;61(1):9-15. [pmid: 10695639].
396 Frye MA, Tsai GE, Huggins T, Coyle JT, Post RM. Low cerebrospinal fluid glutamate and glycine in refractory affective disorder. Biol Psychiatry. Jan. 15. 2007;61(2):162-6. [pmid: 16735030].
397 Fu W, White PF. Dexmedetomidine failed to block the acute hyperdynamic response to electroconvulsive therapy. Anesthesiology. Feb. 1999;90(2):422-4. [pmid: 9952147].
398 Fujikawa T, Yokota N, Muraoka M, Yamawaki S. Response of patients with major depression and silent cerebral infarction to antidepressant drug therapy, with emphasis on central nervous system adverse reactions. Stroke. Nov. 1996;27(11):2040-2. [pmid: 8898812].
399 Fujita A, Nakaaki S, Segawa K, Azuma H, Sato K, Arahata K, et al. Memory, attention, and executive functions before and after sine and pulse wave electroconvulsive therapies for treatment-resistant major depression. J Ect. Jun. 2006;22(2):107-12. [pmid: 16801825].
400 Fulton B, Benfield P. Moclobemide. An update of its pharmacological properties and therapeutic use. Drugs. Sep. 1996;52(3):450-74. [pmid: 8875133].
401 Furtado CP, Maller JJ, Fitzgerald PB. A magnetic resonance imaging study of the entorhinal cortex in treatment-resistant depression. Psychiatry Res. Jul. 15. 2008;163(2):133-42. [pmid: 18511243].
402 Gabriel A. Lamotrigine adjunctive treatment in resistant unipolar depression: an open, descriptive study. Depress Anxiety. 2006;23(8):485-8. [pmid: 16845646].
403 Gangadhar BN, Janakiramaiah N, Subbakrishna DK, Praveen J, Reddy AK. Twice versus thrice weekly ECT in melancholia: a double-blind prospective comparison. J Affect Disord. Apr. 1993;27(4):273-8. [pmid: 8509527].
404 Gangadhar BN, Kapur RL, Kalyanasundaram S. Comparison of electroconvulsive therapy with imipramine in endogenous depression: a double blind study. Br J Psychiatry. Oct. 1982;141:367-71. [pmid: 6756530].
405 Gangadhar BN, Subbakrishna DK, Janakiramaiah N, Motreja S, Narayana Dutt D, Paramehwara G. Post-seizure EEG fractal dimension of first ECT predicts antidepressant response at two weeks. J Affect Disord. Jan-Mar. 1999;52(1-3):235-8. [pmid: 10357038].
406 Garcia-Toro M, Salva J, Daumal J, Andres J, Romera M, Lafau O, et al. High (20-Hz) and low (1-Hz) frequency transcranial magnetic stimulation as adjuvant treatment in medication-resistant depression. Psychiatry Res. Jan. 30. 2006;146(1):53-7. [pmid: 16356697].
407 Garcia-Toro M, Segura C, Gonzalez A, Perello J, Valdivia J, Salazar R, et al. Inefficacy of burst-suppression anesthesia in medication-resistant major depression: a controlled trial. J Ect. Dec. 2001;17(4):284-8. [pmid: 11731731].
408 Gareri P, Falconi U, De Fazio P, De Sarro G. Conventional and new antidepressant drugs in the elderly. Prog Neurobiol. Jul. 2000;61(4):353-96. [pmid: 10727780].
409 Gareri P, Stilo G, Bevacqua I, Mattace R, Ferreri G, De Sarro G. Antidepressant drugs in the elderly. Gen Pharmacol. Apr. 1998;30(4):465-75. [pmid: 9522161].
410 Gastpar M. Clinical originality and new biology of trimipramine. Drugs. 1. 1989;38:43-8. discussion 9-50. [pmid: 2693055].
411 Gaszner P, Miklya I. The use of the synthetic enhancer substances (-)-deprenyl and (-)-BPAP in major depression. Neuropsychopharmacol Hung. Dec. 2004;6(4):210-20. [pmid: 15825677].
412 Gaszner P, Miklya I. Major depression and the synthetic enhancer substances, (-)-deprenyl and R-(-)-1-(benzofuran-2-yl)-2-propylaminopentane. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 2006;30(1):5-14. [pmid: 16023777].
413 Gaynes BN. Identifying difficult-to-treat depression: differential diagnosis, subtypes, and comorbidities. J Clin Psychiatry. 6. 2009;70:10-5. [pmid: 19922739].
414 Gaynes BN, Rush AJ, Trivedi MH, Wisniewski SR, Spencer D, Fava M. The STAR*D study: treating depression in the real world. Cleve Clin J Med. Jan. 2008;75(1):57-66. [pmid: 18236731].
415 Gebretsadik M, Jayaprabhu S, Grossberg GT. Mood disorders in the elderly. Med Clin North Am. Sep. 2006;90(5):789-805. [pmid: 16962842].
416 Geddes J, Butler R. Depressive disorders. Clin Evid. Jun. 2002;(7):867-82. [pmid: 12230711].
417 Gelenberg AJ, Shelton RC, Crits-Christoph P, Keller MB, Dunner DL, Hirschfeld RM, et al. The effectiveness of St. John's Wort in major depressive disorder: a naturalistic phase 2 follow-up in which nonresponders were provided alternate medication. J Clin Psychiatry. Aug. 2004;65(8):1114-9. [pmid: 15323598].
418 Gelzer J. Limits to chemotherapy of depression. Psychopathology. 2. 1986;19:108-17. [pmid: 3554298].
419 George MS, Lisanby SH, Avery D, McDonald WM, Durkalski V, Pavlicova M, et al. Daily left prefrontal transcranial magnetic stimulation therapy for major depressive disorder: a sham-controlled randomized trial. Arch Gen Psychiatry. 2010/05/05. 2010:507-16.
420 George MS, Wassermann EM, Kimbrell TA, Little JT, Williams WE, Danielson AL, et al. Mood improvement following daily left prefrontal repetitive transcranial magnetic stimulation in patients with depression: a placebo-controlled crossover trial. Am J Psychiatry. Dec. 1997;154(12):1752-6. [pmid: 9396958].
421 Georgotas A, Friedman E, McCarthy M, Mann J, Krakowski M, Siegel R, et al. Resistant geriatric depressions and therapeutic response to monoamine oxidase inhibitors. Biol Psychiatry. Feb. 1983;18(2):195-205. [pmid: 6830930].
422 Geretsegger C, Nickel M, Judendorfer B, Rochowanski E, Novak E, Aichhorn W. Propofol and methohexital as anesthetic agents for electroconvulsive therapy: a randomized, double-blind comparison of electroconvulsive therapy seizure quality, therapeutic efficacy, and cognitive performance. J Ect. Dec. 2007;23(4):239-43. [pmid: 18090696].
423 Geretsegger C, Rochowanski E, Kartnig C, Unterrainer AF. Propofol and methohexital as anesthetic agents for electroconvulsive therapy (ECT): a comparison of seizure-quality measures and vital signs. J Ect. Mar. 1998;14(1):28-35. [pmid: 9661091].
424 Gershon AA, Dannon PN, Grunhaus L. Transcranial magnetic stimulation in the treatment of depression. Am J Psychiatry. May. 2003;160(5):835-45. [pmid: 12727683].
425 Gershon S. Chronic pain: hypothesized mechanism and rationale for treatment. Neuropsychobiology. 1. 1986;15:22-7. [pmid: 2873527].
426 Gervasoni N, Aubry JM, Gex-Fabry M, Bertschy G, Bondolfi G. Is there a place for tricyclic antidepressants and subsequent augmentation strategies in obtaining remission for patients with treatment resistant depression?. Pharmacol Res. Mar. 2009;59(3):202-6. [pmid: 19073260].
427 Ghadirian AM, Murphy BE, Gendron MJ. Efficacy of light versus tryptophan therapy in seasonal affective disorder. J Affect Disord. Jul. 1998;50(1):23-7. [pmid: 9716275].
428 Ghaeli P, Shahsavand E, Mesbahi M, Kamkar MZ, Sadeghi M, Dashti-Khavidaki S. Comparing the effects of 8-week treatment with fluoxetine and imipramine on fasting blood glucose of patients with major depressive disorder. J Clin Psychopharmacol. Aug. 2004;24(4):386-8. [pmid: 15232329].
429 Ghaemi SN. Why antidepressants are not antidepressants: STEP-BD, STAR*D, and the return of neurotic depression. Bipolar Disord. Dec. 2008;10(8):957-68. [pmid: 19594510].
430 Giacobbe P, Mayberg HS, Lozano AM. Treatment resistant depression as a failure of brain homeostatic mechanisms: implications for deep brain stimulation. Exp Neurol. Sep. 2009;219(1):44-52. [pmid: 19426730].
431 Gilliam FG, Santos J, Vahle V, Carter J, Brown K, Hecimovic H. Depression in epilepsy: ignoring clinical expression of neuronal network dysfunction?. Epilepsia. 2. 2004;45:28-33. [pmid: 15186342].
432 Gillin JC, Smith-Vaniz A, Schnierow B, Rapaport MH, Kelsoe J, Raimo E, et al. An open-label, 12-week clinical and sleep EEG study of nefazodone in chronic combat-related posttraumatic stress disorder. J Clin Psychiatry. Oct. 2001;62(10):789-96. [pmid: 11816868].
433 Gilmer WS, Gollan JK, Wisniewski SR, Howland RH, Trivedi MH, Miyahara S, et al. Does the duration of index episode affect the treatment outcome of major depressive disorder? A STAR*D report. J Clin Psychiatry. Aug. 2008;69(8):1246-56. [pmid: 18681756].
434 Gitlin MJ. Treatment-resistant depression. West J Med. Nov. 1991;155(5):521. [pmid: 1815398].
435 Gitlin MJ, Weiner H, Fairbanks L, Hershman JM, Friedfeld N. Failure of T3 to potentiate tricyclic antidepressant response. J Affect Disord. Nov-Dec. 1987;13(3):267-72. [pmid: 2960719].
436 Glassman AH. Antidepressant plasma levels revisited. Int Clin Psychopharmacol. Jun. 2. 1994;9:25-30. [pmid: 7930493].
437 Glover DS, Brown GP, Fairburn CG, Shafran R. A preliminary evaluation of cognitive-behaviour therapy for clinical perfectionism: a case series. Br J Clin Psychol. Mar. 2007;46(Pt 1):85-94. [pmid: 17472203].
438 Goff DC, Brotman AW, Waites M, McCormick S. Trial of fluoxetine added to neuroleptics for treatment-resistant schizophrenic patients. Am J Psychiatry. Apr. 1990;147(4):492-4. [pmid: 1969245].
439 Goff DC, Jenike MA. Treatment-resistant depression in the elderly. J Am Geriatr Soc. Jan. 1986;34(1):63-70. [pmid: 3510242].
440 Goldberg JF. The modern pharmacopoeia: a return to depressive realism?. Bipolar Disord. Dec. 2008;10(8):969-72. [pmid: 19594511].
441 Gonzalez-Pinto A, Gutierrez M, Gonzalez N, Elizagarate E, Perez de Heredia JL, Mico JA. Efficacy and safety of venlafaxine-ECT combination in treatment-resistant depression. J Neuropsychiatry Clin Neurosci. Spring. 2002;14(2):206-9. [pmid: 11983797].
442 Goodman WK. Obsessive-compulsive disorder: diagnosis and treatment. J Clin Psychiatry. 18. 1999;60:27-32. [pmid: 10487253].
443 Goodman WK, McDougle CJ, Price LH. Pharmacotherapy of obsessive compulsive disorder. J Clin Psychiatry. Apr. Suppl. 1992;53:29-37. [pmid: 1532962].
444 Goodnick PJ, Sandoval R, Brickman A, Klimas NG. Bupropion treatment of fluoxetine-resistant chronic fatigue syndrome. Biol Psychiatry. Nov. 1. 1992;32(9):834-8. [pmid: 1450297].
445 Gossen D, de Suray JM, Vandenhende F, Onkelinx C, Gangji D. Influence of fluoxetine on olanzapine pharmacokinetics. AAPS PharmSci. 2002;4(2):E11. [pmid: 12102620].
446 Goyal N, Nizamie SH, Desarkar P. Efficacy of adjuvant high frequency repetitive transcranial magnetic stimulation on negative and positive symptoms of schizophrenia: preliminary results of a double-blind sham-controlled study. J Neuropsychiatry Clin Neurosci. Fall. 2007;19(4):464-7. [pmid: 18070852].
447 Gram LF. Inadequate dosing and pharmacokinetic variability as confounding factors in assessment of efficacy of antidepressants. Clin Neuropharmacol. 1. 1990;13:S35-44. [pmid: 2199035].
448 Gram LF. Acute and continuation therapy in unipolar depression: observations from the run-in phase of a maintenance trial. Acta Psychiatr Scand. Aug. 2008;118(2):123-9. [pmid: 18384466].
449 Gran L, Bergsholm P, Bleie H. Seizure duration in unilateral electroconvulsive therapy. A comparison of the anaesthetic agents etomidate and Althesin with methohexitone. Acta Psychiatr Scand. Jun. 1984;69(6):472-83. [pmid: 6741597].
450 Graziottin A, Serafini A. Depression and the menopause: why antidepressants are not enough?. Menopause Int. Jun. 2009;15(2):76-81. [pmid: 19465674].
451 Greden JF, Pande AC. Treatment of resistant depression with 5-HT uptake inhibitors. Clin Neuropharmacol. 1 Pt A. 1992;15:442A-3A.
452 Greenberg BD, Askland KD, Carpenter LL. The evolution of deep brain stimulation for neuropsychiatric disorders. Front Biosci. 2008;13:4638-48. [pmid: 18508535].
453 Greenberg P, Corey-Lisle PK, Birnbaum H, Marynchenko M, Claxton A. Economic implications of treatment-resistant depression among employees. Pharmacoeconomics. 2004;22(6):363-73. [pmid: 15099122].
454 Greenhalgh J, Knight C, Hind D, Beverley C, Walters S. Clinical and cost-effectiveness of electroconvulsive therapy for depressive illness, schizophrenia, catatonia and mania: systematic reviews and economic modelling studies. Health Technol Assess. Mar. 2005;9(9):1-156. iii. iv. [pmid: 15774232].
455 Greenlee BA, Ferrell RB, Kauffman CI, McAllister TW. Complex partial seizures and depression. Curr Psychiatry Rep. Oct. 2003;5(5):410-6. [pmid: 13678563].
456 Gregoire AJ, Kumar R, Everitt B, Henderson AF, Studd JW. Transdermal oestrogen for treatment of severe postnatal depression. Lancet. Apr. 6. 1996;347(9006):930-3. [pmid: 8598756].
457 Grisaru N, Amir M, Cohen H, Kaplan Z. Effect of transcranial magnetic stimulation in posttraumatic stress disorder: a preliminary study. Biol Psychiatry. Jul. 1. 1998;44(1):52-5. [pmid: 9646883].
458 Grisaru N, Chudakov B, Yaroslavsky Y, Belmaker RH. Transcranial magnetic stimulation in mania: a controlled study. Am J Psychiatry. Nov. 1998;155(11):1608-10. [pmid: 9812128].
459 Griskova I, Ruksenas O, Dapsys K, Herpertz S, Hoppner J. The effects of 10 Hz repetitive transcranial magnetic stimulation on resting EEG power spectrum in healthy subjects. Neurosci Lett. May. 29. 2007;419(2):162-7. [pmid: 17478041].
460 Grof P, Joffe R, Kennedy S, Persad E, Syrotiuk J, Bradford D. An open study of oral flesinoxan, a 5-HT1A receptor agonist, in treatment-resistant depression. Int Clin Psychopharmacol. Fall. 1993;8(3):167-72. [pmid: 8263314].
461 Grote NK, Frank E. Difficult-to-treat depression: the role of contexts and comorbidities. Biol Psychiatry. Apr. 15. 2003;53(8):660-70. [pmid: 12706952].
462 Gruber AJ, Hudson JI, Pope HG Jr. The management of treatment-resistant depression in disorders on the interface of psychiatry and medicine. Fibromyalgia, chronic fatigue syndrome, migraine, irritable bowel syndrome, atypical facial pain, and premenstrual dysphoric disorder. Psychiatr Clin North Am. Jun. 1996;19(2):351-69. [pmid: 8827194].
463 Grunhaus L, Hirschman S, Dolberg OT, Schreiber S, Dannon PN. Coadministration of melatonin and fluoxetine does not improve the 3-month outcome following ECT. J Ect. Jun. 2001;17(2):124-8. [pmid: 11417923].
464 Grunhaus L, Polak D, Amiaz R, Dannon PN. Motor-evoked potential amplitudes elicited by transcranial magnetic stimulation do not differentiate between patients and normal controls. Int J Neuropsychopharmacol. Dec. 2003;6(4):371-8. [pmid: 14604452].
465 Grunhaus L, Schreiber S, Dolberg OT, Hirshman S, Dannon PN. Response to ECT in major depression: are there differences between unipolar and bipolar depression?. Bipolar Disord. 1. 2002;4:91-3. [pmid: 12479688].
466 Grunhaus L, Shipley JE, Eiser A, Pande AC, Tandon R, Remen A, et al. Shortened REM latency PostECT is associated with rapid recurrence of depressive symptomatology. Biol Psychiatry. Aug. 15. 1994;36(4):214-22. [pmid: 7986885].
467 Grunhaus L, Shipley JE, Eiser A, Pande AC, Tandon R, Remen A, et al. Polysomnographic studies in patients referred for ECT: pre-ECT studies. Convuls Ther. Dec. 1996;12(4):224-31. [pmid: 9034697].
468 Guscott R, Grof P. The clinical meaning of refractory depression: a review for the clinician. Am J Psychiatry. Jun. 1991;148(6):695-704. [pmid: 2035712].
469 Gutierrez MA, Stimmel GL, Aiso JY. Venlafaxine: a 2003 update. Clin Ther. Aug. 2003;25(8):2138-54. [pmid: 14512125].
470 Gutierrez RL, McKercher RM, Galea J, Jamison KL. Lamotrigine augmentation strategy for patients with treatment-resistant depression. CNS Spectr. Oct. 2005;10(10):800-5. [pmid: 16400242].
471 Haag S, Senf W, Tagay S, Langkafel M, Braun-Lang U, Pietsch A, et al. Is there a benefit from intensified medical and psychological interventions in patients with functional dyspepsia not responding to conventional therapy?. Aliment Pharmacol Ther. Apr. 15. 2007;25(8):973-86. [pmid: 17403002].
472 Hajak G, Marienhagen J, Langguth B, Werner S, Binder H, Eichhammer P. High-frequency repetitive transcranial magnetic stimulation in schizophrenia: a combined treatment and neuroimaging study. Psychol Med. Oct. 2004;34(7):1157-63. [pmid: 15697042].
473 Hallam KT, Smith DI, Berk M. Differences between subjective and objective assessments of the utility of Electroconvulsive therapy in patients with bipolar and unipolar depression. J Affect Disord. Jan. 2009;112(1-3):212-8. [pmid: 18501434].
474 Hamilton M. The effect of treatment on the melancholias (depressions). Br J Psychiatry. Mar. 1982;140:223-30. [pmid: 7093590].
475 Hanaoka N, Aoyama Y, Kameyama M, Fukuda M, Mikuni M. Deactivation and activation of left frontal lobe during and after low-frequency repetitive transcranial magnetic stimulation over right prefrontal cortex: a near-infrared spectroscopy study. Neurosci Lett. Mar. 6. 2007;414(2):99-104. [pmid: 17293047].
476 Hansen PE, Videbech P, Clemmensen K, Sturlason R, Jensen HM, Vestergaard P. Repetitive transcranial magnetic stimulation as add-on antidepressant treatment. The applicability of the method in a clinical setting. Nord J Psychiatry. 2004;58(6):455-7. [pmid: 16195088].
477 Hantouche EG, Akiskal HS, Lancrenon S, Chatenet-Duchene L. Mood stabilizer augmentation in apparently “unipolar” MDD: predictors of response in the naturalistic French national EPIDEP study. J Affect Disord. Feb. 2005;84(2-3):243-9. [pmid: 15708422].
478 Harden CL. The co-morbidity of depression and epilepsy: epidemiology, etiology, and treatment. Neurology. Sep. 24. 2002;59(6 Suppl 4):S48-55. [pmid: 12270969].
479 Hardy BG, Shulman KI, Zucchero C. Gradual discontinuation of lithium augmentation in elderly patients with unipolar depression. J Clin Psychopharmacol. Feb. 1997;17(1):22-6. [pmid: 9004053].
480 Harley R, Sprich S, Safren S, Jacobo M, Fava M. Adaptation of dialectical behavior therapy skills training group for treatment-resistant depression. J Nerv Ment Dis. Feb. 2008;196(2):136-43. [pmid: 18277222].
481 Harrison CL, Ferrier N, Young AH. Tolerability of high-dose venlafaxine in depressed patients. J Psychopharmacol. Jun. 2004;18(2):200-4. [pmid: 15260908].
482 Hartmann PM. Strategies for managing depression complicated by bipolar disorder, suicidal ideation, or psychotic features. J Am Board Fam Pract. Jul-Aug. 1996;9(4):261-9. [pmid: 8829075].
483 Hawley CJ, Quick SJ, Ratnam S, Pattinson HA, McPhee S. Safety and tolerability of combined treatment with moclobemide and SSRIs: a systematic study of 50 patients. Int Clin Psychopharmacol. Sep. 1996;11(3):187-91. [pmid: 8923097].
484 Hawley CJ, Roberts AG, Baldwin DS. Tolerability of combined treatment with lithium and fluoxetine: 14 cases treated under open conditions. Int Clin Psychopharmacol. Spring. 1994;9(1):31-3. [pmid: 8195580].
485 Healey WV, Khan A, Noonan C. Major depression with psychosis: demographic, phenomenological, and outcome characteristics in one hospitalized population. J Nerv Ment Dis. Nov. 1990;178(11):722-3. [pmid: 1977874].
486 Healy D, O'Halloran A, Carney PA, Leonard BE. Variations in platelet 5-hydroxytryptamine in control and depressed populations. J Psychiatr Res. 1986;20(4):345-53. [pmid: 3806429].
487 Healy D, Theodorou AE, Whitehouse AM, Lawrence KM, White W, Wilton-Cox H, et al. 3H-imipramine binding to previously frozen platelet membranes from depressed patients, before and after treatment. Br J Psychiatry. Aug. 1990;157:208-15. [pmid: 2224370].
488 Heijnen WT, van den Broek WW, Birkenhager TK. Treatment failure with a tricyclic antidepressant followed by lithium addition and response to subsequent electroconvulsive therapy. J Clin Psychiatry. Dec. 2008;69(12):1887-91. [pmid: 19014754].
489 Heikman P, Kalska H, Katila H, Sarna S, Tuunainen A, Kuoppasalmi K. Right unilateral and bifrontal electroconvulsive therapy in the treatment of depression: a preliminary study. J Ect. Mar. 2002;18(1):26-30. [pmid: 11925518].
490 Heikman P, Katila H, Sarna S, Wahlbeck K, Kuoppasalmi K. Differential response to right unilateral ECT in depressed patients: impact of comorbidity and severity of illness [ISRCTN39974945]. BMC Psychiatry. 2002;2:2. [pmid: 11846888].
491 Heikman P, Tuunainen A, Kuoppasalmi K. Value of the initial stimulus dose in right unilateral and bifrontal electroconvulsive therapy. Psychol Med. Nov. 1999;29(6):1417-23. [pmid: 10616948].
492 Heit S, Nemeroff CB. Lithium augmentation of antidepressants in treatment-refractory depression. J Clin Psychiatry. 6. 1998;59:28-33. discussion 4. [pmid: 9674934].
493 Heldt E, Manfro GG, Kipper L, Blaya C, Maltz S, Isolan L, et al. Treating medication-resistant panic disorder: predictors and outcome of cognitive-behavior therapy in a Brazilian public hospital. Psychother Psychosom. Jan-Feb. 2003;72(1):43-8. [pmid: 12466637].
494 Heninger GR, Charney DS, Sternberg DE. Lithium carbonate augmentation of antidepressant treatment. An effective prescription for treatment-refractory depression. Arch Gen Psychiatry. Dec. 1983;40(12):1335-42. [pmid: 6418110].
495 Henry ME, Schmidt ME, Matochik JA, Stoddard EP, Potter WZ. The effects of ECT on brain glucose: a pilot FDG PET study. J Ect. Mar. 2001;17(1):33-40. [pmid: 11281513].
496 Herbsman T, Avery D, Ramsey D, Holtzheimer P, Wadjik C, Hardaway F, et al. More lateral and anterior prefrontal coil location is associated with better repetitive transcranial magnetic stimulation antidepressant response. Biol Psychiatry. 2009/06/24. 2009:509-15.
497 Heresco-Levy U, Javitt DC, Gelfin Y, Gorelik E, Bar M, Blanaru M, et al. Controlled trial of D-cycloserine adjuvant therapy for treatment-resistant major depressive disorder. J Affect Disord. Jul. 2006;93(1-3):239-43. [pmid: 16677714].
498 Hermesh H, Aizenberg D, Munitz H. Trazodone treatment in clomipramine-resistant obsessive-compulsive disorder. Clin Neuropharmacol. Aug. 1990;13(4):322-8. [pmid: 2119885].
499 Herr BE, Abraham HD, Anderson W. Length of stay in a general hospital psychiatric unit. Gen Hosp Psychiatry. Jan. 1991;13(1):68-70. [pmid: 1993522].
500 Herwig U, Cardenas-Morales L, Connemann BJ, Kammer T, Schonfeldt-Lecuona C. Sham or real--post hoc estimation of stimulation condition in a randomized transcranial magnetic stimulation trial. Neurosci Lett. Feb. 26. 2010;471(1):30-3. [pmid: 20064587].
501 Herwig U, Fallgatter AJ, Hoppner J, Eschweiler GW, Kron M, Hajak G, et al. Antidepressant effects of augmentative transcranial magnetic stimulation: randomised multicentre trial. Br J Psychiatry. Nov. 2007;191:441-8. [pmid: 17978325].
502 Herwig U, Padberg F, Unger J, Spitzer M, Schonfeldt-Lecuona C. Transcranial magnetic stimulation in therapy studies: examination of the reliability of “standard” coil positioning by neuronavigation. Biol Psychiatry. Jul. 1. 2001;50(1):58-61. [pmid: 11457424].
503 Hickie I, Bennett B, Mitchell P, Wilhelm K, Orlay W. Clinical and subclinical hypothyroidism in patients with chronic and treatment-resistant depression. Aust N Z J Psychiatry. Apr. 1996;30(2):246-52. [pmid: 8811268].
504 Hickie I, Mason C, Parker G. Comparative validity of two measures of psychomotor function in patients with severe depression. J Affect Disord. Apr. 12. 1996;37(2-3):143-9. [pmid: 8731077].
505 Hickie I, Mason C, Parker G, Brodaty H. Prediction of ECT response: validation of a refined sign-based (CORE) system for defining melancholia. Br J Psychiatry. Jul. 1996;169(1):68-74. [pmid: 8818371].
506 Hill MN, Gorzalka BB. Is there a role for the endocannabinoid system in the etiology and treatment of melancholic depression?. Behav Pharmacol. Sep. 2005;16(5-6):333-52. [pmid: 16148438].
507 Hirschfeld RM. Efficacy of SSRIs and newer antidepressants in severe depression: comparison with TCAs. J Clin Psychiatry. May. 1999;60(5):326-35. [pmid: 10362442].
508 Hirschfeld RM. The use of mirtazapine in difficult-to-treat patient populations. Hum Psychopharmacol. Jun. 1. 2002;17:S33-6. [pmid: 12404668].
509 Hirschfeld RM, Lewis L, Vornik LA. Perceptions and impact of bipolar disorder: how far have we really come? Results of the national depressive and manic-depressive association 2000 survey of individuals with bipolar disorder. J Clin Psychiatry. Feb. 2003;64(2):161-74. [pmid: 12633125].
510 Hoencamp E, Haffmans J, Dijken WA, Huijbrechts IP. Lithium augmentation of venlafaxine: an open-label trial. J Clin Psychopharmacol. Oct. 2000;20(5):538-43. [pmid: 11001238].
511 Hoeppner J, Padberg F, Domes G, Zinke A, Herpertz SC, Grossheinrich N, et al. Influence of repetitive transcranial magnetic stimulation on psychomotor symptoms in major depression. Eur Arch Psychiatry Clin Neurosci. Apr. 2010;260(3):197-202. [pmid: 19680706].
512 Hofmann P, Gangadhar BN, Probst C, Koinig G, Hatzinger R. TSH response to TRH and ECT. J Affect Disord. Oct. 1994;32(2):127-31. [pmid: 7829764].
513 Hoiriis KT, Pfleger B, McDuffie FC, Cotsonis G, Elsangak O, Hinson R, et al. A randomized clinical trial comparing chiropractic adjustments to muscle relaxants for subacute low back pain. J Manipulative Physiol Ther. Jul-Aug. 2004;27(6):388-98. [pmid: 15319761].
514 Holm KJ, Markham A. Mirtazapine: a review of its use in major depression. Drugs. Apr. 1999;57(4):607-31. [pmid: 10235695].
515 Holsboer F. Prediction of clinical course by dexamethasone suppression test (DST) response in depressed patients - physiological and clinical construct validity of the DST. Pharmacopsychiatria. Nov. 1983;16(6):186-91. [pmid: 6665028].
516 Holtzheimer PE 3rd, Russo J, Claypoole KH, Roy-Byrne P, Avery DH. Shorter duration of depressive episode may predict response to repetitive transcranial magnetic stimulation. Depress Anxiety. 2004;19(1):24-30. [pmid: 14978782].
517 Holzer M, Padberg F. Intermittent theta burst stimulation (iTBS) ameliorates therapy-resistant depression: a case series. Brain Stimul. Jul. 2010;3(3):181-3. [pmid: 20633448].
518 Hong CJ, Wang YC, Tsai SJ. Association study of angiotensin I-converting enzyme polymorphism and symptomatology and antidepressant response in major depressive disorders. J Neural Transm. Sep. 2002;109(9):1209-14. [pmid: 12203048].
519 Honkonen TI, Aro TA, Isometsa ET, Virtanen EM, Katila HO. Quality of treatment and disability compensation in depression: comparison of 2 nationally representative samples with a 10-year interval in Finland. J Clin Psychiatry. Dec. 2007;68(12):1886-93. [pmid: 18162019].
520 Horne RL, Pettinati HM, Sugerman AA, Varga E. Comparing bilateral to unilateral electroconvulsive therapy in a randomized study with EEG monitoring. Arch Gen Psychiatry. Nov. 1985;42(11):1087-92. [pmid: 3901956].
521 Hornig M, Mozley PD, Amsterdam JD. HMPAO SPECT brain imaging in treatment-resistant depression. Prog Neuropsychopharmacol Biol Psychiatry. Oct. 1997;21(7):1097-114. [pmid: 9421825].
522 Hornig-Rohan M, Wolkowitz OM, Amsterdam JD. Novel strategies for treatment-resistant depression. Psychiatr Clin North Am. Jun. 1996;19(2):387-405. [pmid: 8827196].
523 House A, Bostock J, Cooper J. Depressive syndromes in the year following onset of a first schizophrenic illness*. Br J Psychiatry. Dec. 1987;151:773-9. [pmid: 2901885].
524 Howland RH. Pharmacotherapy strategies for treatment-resistant depression. J Psychosoc Nurs Ment Health Serv. Nov. 2006;44(11):11-4.
525 Howland RH. Therapeutic armamentarium for treating depression. Postgrad Med. Jul. 2010;122(4):66-93. [pmid: 20675972].
526 Hsieh MH, McQuoid DR, Levy RM, Payne ME, MacFall JR, Steffens DC. Hippocampal volume and antidepressant response in geriatric depression. Int J Geriatr Psychiatry. Jun. 2002;17(6):519-25. [pmid: 12112175].
527 Huang CC, Su TP, Wei IH. Repetitive transcranial magnetic stimulation for treating medication-resistant depression in Taiwan: a preliminary study. J Chin Med Assoc. May. 2005;68(5):210-5. [pmid: 15909725].
528 Huang CC, Wei IH, Chou YH, Su TP. Effect of age, gender, menopausal status, and ovarian hormonal level on rTMS in treatment-resistant depression. Psychoneuroendocrinology. Jul. 2008;33(6):821-31. [pmid: 18468810].
529 Hung YY, Huang TL. Lorazepam and diazepam rapidly relieve catatonic features in major depression. Clin Neuropharmacol. May-Jun. 2006;29(3):144-7. [pmid: 16772813].
530 Husain MM, McClintock SM, Rush AJ, Knapp RG, Fink M, Rummans TA, et al. The efficacy of acute electroconvulsive therapy in atypical depression. J Clin Psychiatry. Mar. 2008;69(3):406-11. [pmid: 18278988].
531 Husain MM, Rush AJ, Fink M, Knapp R, Petrides G, Rummans T, et al. Speed of response and remission in major depressive disorder with acute electroconvulsive therapy (ECT): a Consortium for Research in ECT (CORE) report. J Clin Psychiatry. Apr. 2004;65(4):485-91. [pmid: 15119910].
532 Husain SS, Kevan IM, Linnell R, Scott AI. Electroconvulsive therapy in depressive illness that has not responded to drug treatment. J Affect Disord. Dec. 2004;83(2-3):121-6. [pmid: 15555704].
533 Husain SS, Kevan IM, Linnell R, Scott AI. What do psychiatrists mean by medication resistance as an indication for electroconvulsive therapy?. J Ect. Dec. 2005;21(4):211-3. [pmid: 16301879].
534 Huuhka K, Kampman O, Anttila S, Huuhka M, Rontu R, Mattila KM, et al. RGS4 polymorphism and response to electroconvulsive therapy in major depressive disorder. Neurosci Lett. May. 23. 2008;437(1):25-8. [pmid: 18434012].
535 Huuhka M, Korpisammal L, Haataja R, Leinonen E. One-year outcome of elderly inpatients with major depressive disorder treated with ECT and antidepressants. J Ect. Sep. 2004;20(3):179-85. [pmid: 15343003].
536 Huuhka MJ, Haanpaa ML, Leinonen EV. Electroconvulsive therapy in patients with depression and fibromyalgia. Eur J Pain. Aug. 2004;8(4):371-6. [pmid: 15207518].
537 Ide M, Kadoi Y, Saito S, Takahashi K, Sawano Y, Miyazaki M, et al. Effects of landiolol on left ventricular function during electroconvulsive therapy: a transthoracic echocardiographic study. J Anesth. Apr. 2010;24(2):272-6. [pmid: 20140462].
538 Ikeji OC, Ohaeri JU, Osahon RO, Agidee RO. Naturalistic comparative study of outcome and cognitive effects of unmodified electro-convulsive therapy in schizophrenia, mania and severe depression in Nigeria. East Afr Med J. Nov. 1999;76(11):644-50. [pmid: 10734527].
539 Inglot AD, Leszek J, Piasecki E, Sypula A. Interferon responses in schizophrenia and major depressive disorders. Biol Psychiatry. Apr. 1. 1994;35(7):464-73. [pmid: 7517191].
540 Ingram A, Schweitzer I, Ng CH, Saling MM, Savage G. A comparison of propofol and thiopentone use in electroconvulsive therapy: cognitive and efficacy effects. J Ect. Sep. 2007;23(3):158-62. [pmid: 17804989].
541 Inoue T, Nakagawa S, Kitaichi Y, Izumi T, Tanaka T, Masui T, et al. Long-term outcome of antidepressant-refractory depression: the relevance of unrecognized bipolarity. J Affect Disord. Oct. 2006;95(1-3):61-7. [pmid: 16797078].
542 Inoue T, Tsuchiya K, Miura J, Sakakibara S, Denda K, Kasahara T, et al. Bromocriptine treatment of tricyclic and heterocyclic antidepressant-resistant depression. Biol Psychiatry. Jul. 15. 1996;40(2):151-3. [pmid: 8793048].
543 Isometsa ET, Henriksson MM, Aro HM, Heikkinen ME, Kuoppasalmi KI, Lonnqvist JK. Suicide in major depression. Am J Psychiatry. Apr. 1994;151(4):530-6. [pmid: 8147450].
544 Ivkovic M, Damjanovic A, Jovanovic A, Cvetic T, Jasovic-Gasic M. Lamotrigine versus lithium augmentation of antidepressant therapy in treatment-resistant depression: efficacy and tolerability. Psychiatr Danub. Jun. 2009;21(2):187-93. [pmid: 19556947].
545 Jagadeesh HN, Gangadhar BN, Janakiramaiah N, Subbakrishna DK, Jain S. Time dependent therapeutic effects of single electroconvulsive therapy (ECT) in endogenous depression. J Affect Disord. Apr. 1992;24(4):291-5. [pmid: 1578085].
546 Janakiramaiah N, Gangadhar BN, Naga Venkatesha, Murthy PJ, Harish MG, Subbakrishna DK, Vedamurthachar A. Antidepressant efficacy of Sudarshan Kriya Yoga (SKY) in melancholia: a randomized comparison with electroconvulsive therapy (ECT) and imipramine. J Affect Disord. Jan-Mar. 2000;57(1-3):255-9. [pmid: 10708840].
547 Janicak PG, Dowd SM, Martis B, Alam D, Beedle D, Krasuski J, et al. Repetitive transcranial magnetic stimulation versus electroconvulsive therapy for major depression: preliminary results of a randomized trial. Biol Psychiatry. Apr. 15. 2002;51(8):659-67. [pmid: 11955466].
548 Janicak PG, Martis B. Strategies for treatment-resistant depression. Clin Cornerstone. 1999;1(4):58-71. [pmid: 10682177].
549 Janicak PG, O'Reardon JP, Sampson SM, Husain MM, Lisanby SH, Rado JT, et al. Transcranial magnetic stimulation in the treatment of major depressive disorder: a comprehensive summary of safety experience from acute exposure, extended exposure, and during reintroduction treatment. J Clin Psychiatry. Feb. 2008;69(2):222-32. [pmid: 18232722].
550 Janicak PG, Sharma RP, Israni TH, Dowd SM, Altman E, Davis JM. Effects of unilateral-nondominant vs. bilateral ECT on memory and depression: a preliminary report. Psychopharmacol Bull. 1991;27(3):353-7. [pmid: 1775610].
551 Jann MW, Slade JH. Antidepressant agents for the treatment of chronic pain and depression. Pharmacotherapy. Nov. 2007;27(11):1571-87. [pmid: 17963465].
552 Januel D, Dumortier G, Verdon CM, Stamatiadis L, Saba G, Cabaret W, et al. A double-blind sham controlled study of right prefrontal repetitive transcranial magnetic stimulation (rTMS): therapeutic and cognitive effect in medication free unipolar depression during 4 weeks. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 2006;30(1):126-30. [pmid: 16242826].
553 Januel D, Massot O, Poirier MF, Olie JP, Fillion G. Interaction of lithium with 5-HT(1B) receptors in depressed unipolar patients treated with clomipramine and lithium versus clomipramine and placebo: preliminary results. Psychiatry Res. Aug. 30. 2002;111(2-3):117-24. [pmid: 12374629].
554 Januel D, Poirier MF, D'Alche-Biree F, Dib M, Olie JP. Multicenter double-blind randomized parallel-group clinical trial of efficacy of the combination clomipramine (150 mg/day) plus lithium carbonate (750 mg/day) versus clomipramine (150 mg/day) plus placebo in the treatment of unipolar major depression. J Affect Disord. Sep. 2003;76(1-3):191-200. [pmid: 12943949].
555 Jenike MA. Treatment of affective illness in the elderly with drugs and electroconvulsive therapy. J Geriatr Psychiatry. 1989;22(1):77-112. discussion 3-20. [pmid: 2691555].
556 Jenike MA. An update on obsessive-compulsive disorder. Bull Menninger Clin. Winter. 2001;65(1):4-25. [pmid: 11280957].
557 Jha A, Stein G. Decreased efficacy of combined benzodiazepines and unilateral ECT in treatment of depression. Acta Psychiatr Scand. Aug. 1996;94(2):101-4. [pmid: 8883570].
558 Joffe RT. Peripheral thyroid hormone levels in treatment resistant depression. Biol Psychiatry. Apr. 15. 1999;45(8):1053-5. [pmid: 10386190].
559 Joffe RT, Bakish D. Combined SSRI-moclobemide treatment of psychiatric illness. J Clin Psychiatry. Jan. 1994;55(1):24-5. [pmid: 8294388].
560 Joffe RT, Levitt AJ, Sokolov ST. Augmentation strategies: focus on anxiolytics. J Clin Psychiatry. 7. 1996;57:25-31. discussion 2-3. [pmid: 8690693].
561 Joffe RT, Schuller DR. An open study of buspirone augmentation of serotonin reuptake inhibitors in refractory depression. J Clin Psychiatry. Jul. 1993;54(7):269-71. [pmid: 8335654].
562 Joffe RT, Singer W, Levitt AJ, MacDonald C. A placebo-controlled comparison of lithium and triiodothyronine augmentation of tricyclic antidepressants in unipolar refractory depression. Arch Gen Psychiatry. May. 1993;50(5):387-93. [pmid: 8489327].
563 Joffe RT, Sokolov ST, Levitt AJ. Lithium and triiodothyronine augmentation of antidepressants. Can J Psychiatry. Oct. 2006;51(12):791-3. [pmid: 17168254].
564 Joffe RT, Sokolov ST, Singer W. Thyroid hormone treatment of depression. Thyroid. Jun. 1995;5(3):235-9. [pmid: 7580274].
565 Johanson A, Gustafson L, Risberg J, Rosen I, Sjobeck M, Silfverskiold P. Long-term follow-up in depressed patients treated with electroconvulsive therapy. J Ect. Dec. 2005;21(4):214-20. [pmid: 16301880].
566 Johansson M, Ehnvall A, Friberg P, Myredal A. Arterial baroreflex dysfunction in major depressive disorder. Clin Auton Res. Aug. 2010;20(4):235-40. [pmid: 20127136].
567 Johnson GF. Lithium in depression: a review of the antidepressant and prophylactic effects of lithium. Aust N Z J Psychiatry. Sep. 1987;21(3):356-65. [pmid: 3325026].
568 Johnstone EC, Deakin JF, Lawler P, Frith CD, Stevens M, McPherson K, et al. The Northwick Park electroconvulsive therapy trial. Lancet. 1980:1317-20.
569 Jorge RE, Moser DJ, Acion L, Robinson RG. Treatment of vascular depression using repetitive transcranial magnetic stimulation. Arch Gen Psychiatry. Mar. 2008;65(3):268-76. [pmid: 18316673].
570 Jorge RE, Robinson RG, O'Brien J. Top cited papers in international psychogeriatrics: 5. A controlled study of repetitive transcranial magnetic stimulation as a treatment of depression in the elderly. Int Psychogeriatr. Oct. 2009;21(5):855-60. [pmid: 19589195].
571 Jorge RE, Robinson RG, Tateno A, Narushima K, Acion L, Moser D, et al. Repetitive transcranial magnetic stimulation as treatment of poststroke depression: a preliminary study. Biol Psychiatry. Feb. 15. 2004;55(4):398-405. [pmid: 14960293].
572 Joseph MH, Risby D, Crow TJ, Deakin JF, Johnstone EC, Lawler P. MHPG excretion in endogenous depression: relationship to clinical state and the effects of ECT. Psychopharmacology (Berl). 1985;87(4):442-8. [pmid: 2867575].
573 Kahkonen S, Komssi S, Wilenius J, Ilmoniemi RJ. Prefrontal TMS produces smaller EEG responses than motor-cortex TMS: implications for rTMS treatment in depression. Psychopharmacology (Berl). Aug. 2005;181(1):16-20. [pmid: 15719214].
574 Kalb R, Ellinger K, Reulbach U. Improvement in response times for simple and complex tasks after electroconvulsive therapy. Prog Neuropsychopharmacol Biol Psychiatry. May. 2003;27(3):459-65. [pmid: 12691781].
575 Kamholz BA, Mellow AM. Management of treatment resistance in the depressed geriatric patient. Psychiatr Clin North Am. Jun. 1996;19(2):269-86. [pmid: 8827190].
576 Kantor D, McNevin S, Leichner P, Harper D, Krenn M. The benefit of lithium carbonate adjunct in refractory depression--fact or fiction?. Can J Psychiatry. Jun. 1986;31(5):416-8. [pmid: 3089576].
577 Kaplan R. Obstructive sleep apnoea and depression--diagnostic and treatment implications. Aust N Z J Psychiatry. Dec. 1992;26(4):586-91. [pmid: 1476523].
578 Karp JF, Whyte EM, Lenze EJ, Dew MA, Begley A, Miller MD, et al. Rescue pharmacotherapy with duloxetine for selective serotonin reuptake inhibitor nonresponders in late-life depression: outcome and tolerability. J Clin Psychiatry. Mar. 2008;69(3):457-63. [pmid: 18251622].
579 Kasper S. The rationale for long-term antidepressant therapy. Int Clin Psychopharmacol. Winter. 1993;8(4):225-35. [pmid: 8277140].
580 Kato M, Fukuda T, Serretti A, Wakeno M, Okugawa G, Ikenaga Y, et al. ABCB1 (MDR1) gene polymorphisms are associated with the clinical response to paroxetine in patients with major depressive disorder. Prog Neuropsychopharmacol Biol Psychiatry. Feb. 15. 2008;32(2):398-404. [pmid: 17913323].
581 Katona CL. Puerperal mental illness: comparisons with non-puerperal controls. Br J Psychiatry. Nov. 1982;141:447-52. [pmid: 7150880].
582 Katona CL. Lithium augmentation in refractory depression. Psychiatr Dev. Summer. 1988;6(2):153-71. [pmid: 3070547].
583 Katona CL. Refractory depression: a review with particular reference to the use of lithium augmentation. Eur Neuropsychopharmacol. Suppl. 1995;5:109-13. [pmid: 8775769].
584 Katz MM, Koslow SH, Maas JW, Frazer A, Kocsis J, Secunda S, et al. Identifying the specific clinical actions of amitriptyline: interrelationships of behaviour, affect and plasma levels in depression. Psychol Med. Aug. 1991;21(3):599-611. [pmid: 1946849].
585 Kaymaz N, van Os J, Loonen AJ, Nolen WA. Evidence that patients with single versus recurrent depressive episodes are differentially sensitive to treatment discontinuation: a meta-analysis of placebo-controlled randomized trials. J Clin Psychiatry. Sep. 2008;69(9):1423-36. [pmid: 19193343].
586 Keeley R, Smith M, Miller J. Somatoform symptoms and treatment nonadherence in depressed family medicine outpatients. Arch Fam Med. Jan. 2000;9(1):46-54. [pmid: 10664642].
587 Keitner GI, Ryan CE, Solomon DA. Realistic expectations and a disease management model for depressed patients with persistent symptoms. J Clin Psychiatry. Sep. 2006;67(9):1412-21. [pmid: 17017828].
588 Keks NA, Burrows GD, Copolov DL, Newton R, Paoletti N, Schweitzer I, et al. Beyond the evidence: is there a place for antidepressant combinations in the pharmacotherapy of depression?. Med J Aust. Feb. 5. 2007;186(3):142-4. [pmid: 17309404].
589 Keller MB. Issues in treatment-resistant depression. J Clin Psychiatry. 8. 2005;66:5-12. [pmid: 16336031].
590 Keller MB, Shapiro RW. Major depressive disorder. Initial results from a one-year prospective naturalistic follow-up study. J Nerv Ment Dis. Dec. 1981;169(12):761-8. [pmid: 7310387].
591 Kellner CH, Husain M, Petrides G, Fink M, Rummans T. Comment on “Repetitive transcranial magnetic stimulation versus electroconvulsive therapy for major depression: preliminary results of a randomized trial”. Biol Psychiatry. Nov. 15. 2002;52(10):1032. 3. discussion 3. [pmid: 12437944].
592 Kellner CH, Knapp R, Husain MM, Rasmussen K, Sampson S, Cullum M, et al. Bifrontal, bitemporal and right unilateral electrode placement in ECT: randomised trial. Br J Psychiatry. Mar. 2010;196:226-34. [pmid: 20194546].
593 Kellner CH, Knapp RG, Petrides G, Rummans TA, Husain MM, Rasmussen K, et al. Continuation electroconvulsive therapy vs pharmacotherapy for relapse prevention in major depression: a multisite study from the Consortium for Research in Electroconvulsive Therapy (CORE). Arch Gen Psychiatry. 2006:1337-44.
594 Kelly TF, Lieberman DZ. Long term augmentation with T3 in refractory major depression. J Affect Disord. May. 2009;115(1-2):230-3. [pmid: 19108898].
595 Kelway B, Simpson KH, Smith RJ, Halsall PJ. Effects of atropine and glycopyrrolate on cognitive function following anaesthesia and electroconvulsive therapy (ECT). Int Clin Psychopharmacol. Oct. 1986;1(4):296-302. [pmid: 3549875].
596 Kennedy N, Paykel ES. Treatment and response in refractory depression: results from a specialist affective disorders service. J Affect Disord. Jul. 2004;81(1):49-53. [pmid: 15183599].
597 Kennedy SH, Joffe RT. Pharmacological management of refractory depression. Can J Psychiatry. Jun. 1989;34(5):451-6. [pmid: 2670176].
598 Kennedy SH, Lam RW, Cohen NL, Rosenbluth M, Sokolov ST, McIntyre RS, et al. Reboxetine: a preliminary report on its use through the Special Access Program. J Psychiatry Neurosci. Nov. 2002;27(6):418-22. [pmid: 12491574].
599 Kennedy SH, Milev R, Giacobbe P, Ramasubbu R, Lam RW, Parikh SV, et al. Canadian Network for Mood and Anxiety Treatments (CANMAT) Clinical guidelines for the management of major depressive disorder in adults. IV. Neurostimulation therapies. J Affect Disord. Oct. 1. 2009;117:S44-53. [pmid: 19656575].
600 Ketter TA, Post RM, Parekh PI, Worthington K. Addition of monoamine oxidase inhibitors to carbamazepine: preliminary evidence of safety and antidepressant efficacy in treatment-resistant depression. J Clin Psychiatry. Oct. 1995;56(10):471-5. [pmid: 7559374].
601 Khalid N, Atkins M, Tredget J, Giles M, Champney-Smith K, Kirov G. The effectiveness of electroconvulsive therapy in treatment-resistant depression: a naturalistic study. J Ect. Jun. 2008;24(2):141-5. [pmid: 18580559].
602 Khan A, Johnson F, Avery DH, Cohen S, Scherzo B, Dunner DL. DST results in nonpsychotic depressed outpatients. Am J Psychiatry. Sep. 1988;145(9):1153-6. [pmid: 3046385].
603 Khan A, Mirolo MH, Claypoole K, Bhang J, Cox G, Horita A, et al. Effects of low-dose TRH on cognitive deficits in the ECT postictal state. Am J Psychiatry. Nov. 1994;151(11):1694-6. [pmid: 7943463].
604 Kielholz P. Treatment for therapy-resistant depression. Psychopathology. 2. 1986;19:194-200. [pmid: 2883699].
605 Kikuchi A, Yasui-Furukori N, Fujii A, Katagai H, Kaneko S. Identification of predictors of post-ictal delirium after electroconvulsive therapy. Psychiatry Clin Neurosci. Apr. 2009;63(2):180-5. [pmid: 19335388].
606 Kiloh LG. Non-pharmacological biological treatments of psychiatric patients. Aust N Z J Psychiatry. Sep. 1983;17(3):215-25. [pmid: 6360121].
607 Kimball JN, Rosenquist PB, Dunn A, McCall V. Prediction of antidepressant response in both 2.25xthreshold RUL and fixed high dose RUL ECT. J Affect Disord. Jan. 2009;112(1-3):85-91. [pmid: 18539340].
608 Kimbrell TA, Little JT, Dunn RT, Frye MA, Greenberg BD, Wassermann EM, et al. Frequency dependence of antidepressant response to left prefrontal repetitive transcranial magnetic stimulation (rTMS) as a function of baseline cerebral glucose metabolism. Biol Psychiatry. Dec. 15. 1999;46(12):1603-13. [pmid: 10624541].
609 Kirchheiner J, Bertilsson L, Bruus H, Wolff A, Roots I, Bauer M. Individualized medicine - implementation of pharmacogenetic diagnostics in antidepressant drug treatment of major depressive disorders. Pharmacopsychiatry. Nov. 3. 2003;36:S235-43. [pmid: 14677085].
610 Kirkby KC, Beckett WG, Matters RM, King TE. Comparison of propofol and methohexitone in anaesthesia for ECT: effect on seizure duration and outcome. Aust N Z J Psychiatry. Jun. 1995;29(2):299-303. [pmid: 7487795].
611 Kirov G, Ebmeier KP, Scott AI, Atkins M, Khalid N, Carrick L, et al. Quick recovery of orientation after magnetic seizure therapy for major depressive disorder. Br J Psychiatry. Aug. 2008;193(2):152-5. [pmid: 18670002].
612 Kito S, Fujita K, Koga Y. Regional cerebral blood flow changes after low-frequency transcranial magnetic stimulation of the right dorsolateral prefrontal cortex in treatment-resistant depression. Neuropsychobiology. 2008;58(1):29-36. [pmid: 18781088].
613 Kito S, Fujita K, Koga Y. Changes in regional cerebral blood flow after repetitive transcranial magnetic stimulation of the left dorsolateral prefrontal cortex in treatment-resistant depression. J Neuropsychiatry Clin Neurosci. Winter. 2008;20(1):74-80. [pmid: 18305287].
614 Kito S, Hasegawa T, Fujita K, Koga Y. Changes in hypothalamic-pituitary-thyroid axis following successful treatment with low-frequency right prefrontal transcranial magnetic stimulation in treatment-resistant depression. Psychiatry Res. Jan. 30. 2010;175(1-2):74-7. [pmid: 20004482].
615 Klein E, Kreinin I, Chistyakov A, Koren D, Mecz L, Marmur S, et al. Therapeutic efficacy of right prefrontal slow repetitive transcranial magnetic stimulation in major depression: a double-blind controlled study. Arch Gen Psychiatry. Apr. 1999;56(4):315-20. [pmid: 10197825].
616 Klein N, Sacher J, Wallner H, Tauscher J, Kasper S. Therapy of treatment resistant depression: focus on the management of TRD with atypical antipsychotics. CNS Spectr. Nov. 2004;9(11):823-32. [pmid: 15520606].
617 Kocsis JH, Frances A, Kalman TP, Shear MK. The effect of psychobiological research on treatment outcome. A controlled study. Arch Gen Psychiatry. May. 1981;38(5):511-5. [pmid: 7235851].
618 Koerselman F, Laman DM, van Duijn H, van Duijn MA, Willems MA. A 3-month, follow-up, randomized, placebo-controlled study of repetitive transcranial magnetic stimulation in depression. J Clin Psychiatry. Oct. 2004;65(10):1323-8. [pmid: 15491234].
619 Kohn R, Epstein-Lubow G. Course and outcomes of depression in the elderly. Curr Psychiatry Rep. Feb. 2006;8(1):34-40. [pmid: 16513041].
620 Kok RM, Vink D, Heeren TJ, Nolen WA. Lithium augmentation compared with phenelzine in treatment-resistant depression in the elderly: an open, randomized, controlled trial. J Clin Psychiatry. Aug. 2007;68(8):1177-85. [pmid: 17854241].
621 Konarski JZ, Kennedy SH, Segal ZV, Lau MA, Bieling PJ, McIntyre RS, et al. Predictors of nonresponse to cognitive behavioural therapy or venlafaxine using glucose metabolism in major depressive disorder. J Psychiatry Neurosci. May. 2009;34(3):175-80. [pmid: 19448846].
622 Kondziella D, Asztely F. Don't be afraid to treat depression in patients with epilepsy! Acta Neurol Scand. Feb. 2009;119(2):75-80.
623 Konig F, Wolfersdorf M. Combination therapy using moclobemide with tricyclic and tetracyclic antidepressants to treat therapy-resistant depression. Pharmacopsychiatry. May. 1997;30(3):93-6. [pmid: 9211570].
624 Konig F, Wolfersdorf M, Loble M, Wossner S, Hauger B. Trimipramine and maprotiline plasma levels during combined treatment with moclobemide in therapy-resistant depression. Pharmacopsychiatry. Jul. 1997;30(4):125-7. [pmid: 9271778].
625 Kopecek M, Cerna L, Sulak J, Raszka M, Bares M, Seifertova D. Depressed patients perception of the efficacy of electroconvulsive therapy and venlafaxine therapy. Neuro Endocrinol Lett. Dec. 2007;28(6):889-94. [pmid: 18063943].
626 Kopf D, Westphal S, Luley CW, Ritter S, Gilles M, Weber-Hamann B, et al. Lipid metabolism and insulin resistance in depressed patients: significance of weight, hypercortisolism, and antidepressant treatment. J Clin Psychopharmacol. Oct. 2004;24(5):527-31. [pmid: 15349009].
627 Kornbluh R, Papakostas GI, Petersen T, Neault NB, Nierenberg AA, Rosenbaum JF, et al. A survey of prescribing preferences in the treatment of refractory depression: recent trends. Psychopharmacol Bull. Summer. 2001;35(3):150-6. [pmid: 12397884].
628 Kornstein SG, Schneider RK. Clinical features of treatment-resistant depression. J Clin Psychiatry. 16. 2001;62:18-25. [pmid: 11480880].
629 Kostowski W. Recent advances in the GABA-A-benzodiazepine receptor pharmacology. Pol J Pharmacol. May-Jun. 1995;47(3):237-46. [pmid: 8714756].
630 Kotresh S, Girish K, Janakiramaiah N, Rao GU, Gangadhar BN. Effect of ECT stimulus parameters on seizure physiology and outcome. J Ect. Mar. 2004;20(1):10-2. [pmid: 15087990].
631 Kraft JB, Peters EJ, Slager SL, Jenkins GD, Reinalda MS, McGrath PJ, et al. Analysis of association between the serotonin transporter and antidepressant response in a large clinical sample. Biol Psychiatry. Mar. 15. 2007;61(6):734-42. [pmid: 17123473].
632 Kral VA, Emery OB. Long-term follow-up of depressive pseudodementia of the aged. Can J Psychiatry. Jun. 1989;34(5):445-6. [pmid: 2766198].
633 Kramlinger KG, Post RM. The addition of lithium to carbamazepine. Antidepressant efficacy in treatment-resistant depression. Arch Gen Psychiatry. Sep. 1989;46(9):794-800. [pmid: 2505730].
634 Krisanaprakornkit T, Paholpak S, Tassaniyom K, Pimpanit V. Transcranial magnetic stimulation for treatment resistant depression: six case reports and review. J Med Assoc Thai. May. 2010;93(5):580-6. [pmid: 20524444].
635 Krog-Meyer I, Kirkegaard C, Kijne B, Lumholtz B, Smith E, Lykke-Olesen L, et al. Prediction of relapse with the TRH test and prophylactic amitriptyline in 39 patients with endogenous depression. Am J Psychiatry. Aug. 1984;141(8):945-8. [pmid: 6431834].
636 Krystal AD, Holsinger T, Weiner RD, Coffey CE. Prediction of the utility of a switch from unilateral to bilateral ECT in the elderly using treatment 2 ictal EEG indices. J Ect. Dec. 2000;16(4):327-37. [pmid: 11314870].
637 Krystal AD, Weiner RD, Gassert D, McCall WV, Coffey CE, Sibert T, et al. The relative ability of three ictal EEG frequency bands to differentiate ECT seizures on the basis of electrode placement, stimulus intensity, and therapeutic response. Convuls Ther. Mar. 1996;12(1):13-24. [pmid: 8777648].
638 Krystal AD, Weiner RD, McCall WV, Shelp FE, Arias R, Smith P. The effects of ECT stimulus dose and electrode placement on the ictal electroencephalogram: an intraindividual crossover study. Biol Psychiatry. Dec. 1. 1993;34(11):759-67. [pmid: 8292679].
639 Kubera M, Kenis G, Bosmans E, Kajta M, Basta-Kaim A, Scharpe S, et al. Stimulatory effect of antidepressants on the production of IL-6. Int Immunopharmacol. Feb. 2004;4(2):185-92. [pmid: 14996410].
640 Kubera M, Lin AH, Kenis G, Bosmans E, van Bockstaele D, Maes M. Anti-Inflammatory effects of antidepressants through suppression of the interferon-gamma/interleukin-10 production ratio. J Clin Psychopharmacol. Apr. 2001;21(2):199-206. [pmid: 11270917].
641 Kubera M, Van Bockstaele D, Maes M. Leukocyte subsets in treatment-resistant major depression. Pol J Pharmacol. Nov-Dec. 1999;51(6):547-9. [pmid: 10817536].
642 Kumari V, Mitterschiffthaler MT, Teasdale JD, Malhi GS, Brown RG, Giampietro V, et al. Neural abnormalities during cognitive generation of affect in treatment-resistant depression. Biol Psychiatry. Oct. 15. 2003;54(8):777-91. [pmid: 14550677].
643 Kunik ME, Pollock BG, Perel JM, Altieri L. Clomipramine in the elderly: tolerance and plasma levels. J Geriatr Psychiatry Neurol. Jul-Sep. 1994;7(3):139-43. [pmid: 7916936].
644 Kuny S, Stassen HH. Cognitive performance in patients recovering from depression. Psychopathology. 1995;28(4):190-207. [pmid: 7480575].
645 Kupfer DJ, Spiker DG. Refractory depression: prediction of non-response by clinical indicators. J Clin Psychiatry. Aug. 1981;42(8):307-12. [pmid: 7251567].
646 Kuroda Y, Motohashi N, Ito H, Ito S, Takano A, Nishikawa T, et al. Effects of repetitive transcranial magnetic stimulation on [11C]raclopride binding and cognitive function in patients with depression. J Affect Disord. Oct. 2006;95(1-3):35-42. [pmid: 16781779].
647 Kwamie Y, Persad E, Stancer H. The use of carbamazepine as an adjunctive medication in the treatment of affective disorders: a clinical report. Can J Psychiatry. Nov. 1984;29(7):605-8. [pmid: 6150757].
648 La Rue A, Spar J, Hill CD. Cognitive impairment in late-life depression: clinical correlates and treatment implications. J Affect Disord. Nov-Dec. 1986;11(3):179-84. [pmid: 2951405].
649 Laage TA. Recognizing the drug-resistant patient in anxiety and depression. Med Clin North Am. Jul. 1988;72(4):897-909. [pmid: 2897513].
650 Lader M. Quality of treatment: what do new antidepressants offer?. Int Clin Psychopharmacol. Mar. 1. 1995;10:5-9. [pmid: 7622812].
651 Lam RW, Hossie H, Solomons K, Yatham LN. Citalopram and bupropion-SR: combining versus switching in patients with treatment-resistant depression. J Clin Psychiatry. Mar. 2004;65(3):337-40. [pmid: 15096072].
652 Lam RW, Wan DD, Cohen NL, Kennedy SH. Combining antidepressants for treatment-resistant depression: a review. J Clin Psychiatry. Aug. 2002;63(8):685-93. [pmid: 12197448].
653 Lambert G, Johansson M, Agren H, Friberg P. Reduced brain norepinephrine and dopamine release in treatment-refractory depressive illness: evidence in support of the catecholamine hypothesis of mood disorders. Arch Gen Psychiatry. Aug. 2000;57(8):787-93. [pmid: 10920468].
654 Lamy S, Bergsholm P, d'Elia G. The antidepressant efficacy of high-dose nondominant long-distance parietotemporal and bitemporal electroconvulsive therapy. Convuls Ther. Mar. 1994;10(1):43-52. [pmid: 8055292].
655 Landen M, Bjorling G, Agren H, Fahlen T. A randomized, double-blind, placebo-controlled trial of buspirone in combination with an SSRI in patients with treatment-refractory depression. J Clin Psychiatry. Dec. 1998;59(12):664-8. [pmid: 9921700].
656 Landen M, Hogberg P, Thase ME. Incidence of sexual side effects in refractory depression during treatment with citalopram or paroxetine. J Clin Psychiatry. Jan. 2005;66(1):100-6. [pmid: 15669895].
657 Landgrebe M, Binder H, Koller M, Eberl Y, Kleinjung T, Eichhammer P, et al. Design of a placebo-controlled, randomized study of the efficacy of repetitive transcranial magnetic stimulation for the treatment of chronic tinntius. BMC Psychiatry. 2008;8:23. [pmid: 18412944].
658 Landgrebe M, Hauser S, Langguth B, Frick U, Hajak G, Eichhammer P. Altered cortical excitability in subjectively electrosensitive patients: results of a pilot study. J Psychosom Res. Mar. 2007;62(3):283-8. [pmid: 17324677].
659 Lang UE, Bajbouj M, Gallinat J, Hellweg R. Brain-derived neurotrophic factor serum concentrations in depressive patients during vagus nerve stimulation and repetitive transcranial magnetic stimulation. Psychopharmacology (Berl). Jul. 2006;187(1):56-9. [pmid: 16767416].
660 Lang UE, Hellweg R, Gallinat J, Bajbouj M. Acute prefrontal cortex transcranial magnetic stimulation in healthy volunteers: no effects on brain-derived neurotrophic factor (BDNF) concentrations in serum. J Affect Disord. Apr. 2008;107(1-3):255-8. [pmid: 17825920].
661 Langer G, Karazman R, Neumark J, Saletu B, Schonbeck G, Grunberger J, et al. Isoflurane narcotherapy in depressive patients refractory to conventional antidepressant drug treatment. A double-blind comparison with electroconvulsive treatment. Neuropsychobiology. 1995;31(4):182-94. [pmid: 7659199].
662 Langguth B, Wiegand R, Kharraz A, Landgrebe M, Marienhagen J, Frick U, et al. Pre-treatment anterior cingulate activity as a predictor of antidepressant response to repetitive transcranial magnetic stimulation (rTMS). Neuro Endocrinol Lett. Oct. 2007;28(5):633-8. [pmid: 17984932].
663 Lapid MI, Rummans TA, Pankratz VS, Appelbaum PS. Decisional capacity of depressed elderly to consent to electroconvulsive therapy. J Geriatr Psychiatry Neurol. Mar. 2004;17(1):42-6. [pmid: 15018698].
664 Lapid MI, Rummans TA, Poole KL, Pankratz VS, Maurer MS, Rasmussen KG, et al. Decisional capacity of severely depressed patients requiring electroconvulsive therapy. J Ect. Jun. 2003;19(2):67-72. [pmid: 12792453].
665 Lattanzi L, Dell'Osso L, Cassano P, Pini S, Rucci P, Houck PR, et al. Pramipexole in treatment-resistant depression: a 16-week naturalistic study. Bipolar Disord. Oct. 2002;4(5):307-14. [pmid: 12479663].
666 Lau MA. New developments in psychosocial interventions for adults with unipolar depression. Curr Opin Psychiatry. Jan. 2008;21(1):30-6. [pmid: 18281838].
667 Lauritzen L, Odgaard K, Clemmesen L, Lunde M, Ohrstrom J, Black C, et al. Relapse prevention by means of paroxetine in ECT-treated patients with major depression: a comparison with imipramine and placebo in medium-term continuation therapy. Acta Psychiatr Scand. Oct. 1996;94(4):241-51. [pmid: 8911559].
668 Lefaucheur JP, Lucas B, Andraud F, Hogrel JY, Bellivier F, Del Cul A, et al. Inter-hemispheric asymmetry of motor corticospinal excitability in major depression studied by transcranial magnetic stimulation. J Psychiatr Res. Apr. 2008;42(5):389-98. [pmid: 17449060].
669 Lehmann HE, Fenton FR, Deutsch M, Feldman S, Engelsmann F. An 11-year follow-up study of 110 depressed patients. Acta Psychiatr Scand. Jul. 1988;78(1):57-65. [pmid: 3176996].
670 Leibenluft E, Noonan BM, Wehr TA. Diurnal variation: reliability of measurement and relationship to typical and atypical symptoms of depression. J Affect Disord. Nov. 1992;26(3):199-204. [pmid: 1460170].
671 Lekwauwa R, McQuoid D, Steffens DC. Hippocampal volume is associated with physician-reported acute cognitive deficits after electroconvulsive therapy. J Geriatr Psychiatry Neurol. Mar. 2006;19(1):21-5. [pmid: 16449756].
672 Lekwauwa RE, McQuoid DR, Steffens DC. Hippocampal volume as a predictor of short-term ECT outcomes in older patients with depression. Am J Geriatr Psychiatry. Oct. 2005;13(10):910-3. [pmid: 16223970].
673 Lenox RH, Peyser JM, Rothschild B, Shipley J, Weaver L. Failure to normalize the dexamethasone suppression test: association with length of illness. Biol Psychiatry. Mar. 1985;20(3):333-7. [pmid: 3978166].
674 Lenox RH, Shipley JE, Peyser JM, Williams JM, Weaver LA. Double-blind comparison of alprazolam versus imipramine in the inpatient treatment of major depressive illness. Psychopharmacol Bull. Winter. 1984;20(1):79-82. [pmid: 6144136].
675 Lenox-Smith AJ, Jiang Q. Venlafaxine extended release versus citalopram in patients with depression unresponsive to a selective serotonin reuptake inhibitor. Int Clin Psychopharmacol. May. 2008;23(3):113-9. [pmid: 18408525].
676 Lenze EJ, Sheffrin M, Driscoll HC, Mulsant BH, Pollock BG, Dew MA, et al. Incomplete response in late-life depression: getting to remission. Dialogues Clin Neurosci. 2008;10(4):419-30. [pmid: 19170399].
677 Leonard BE. Biochemical aspects of therapy-resistant depression. Br J Psychiatry. Apr. 1988;152:453-9. [pmid: 3048524].
678 Leonard BE. Pharmacological and biochemical aspects of therapy-resistant depression. Int Clin Psychopharmacol. Jul. 1. 1991;6:13-28. discussion -9. [pmid: 1757716].
679 Lerer B, Shapira B, Calev A, Tubi N, Drexler H, Kindler S, et al. Antidepressant and cognitive effects of twice- versus three-times-weekly ECT. Am J Psychiatry. Apr. 1995;152(4):564-70. [pmid: 7694905].
680 Lestra C, d'Amato T, Ghaemmaghami C, Perret-Liaudet A, Broyer M, Renaud B, et al. Biological parameters in major depression: effects of paroxetine, viloxazine, moclobemide, and electroconvulsive therapy. Relation to early clinical outcome. Biol Psychiatry. Aug. 15. 1998;44(4):274-80. [pmid: 9715359].
681 Letemendia FJ, Delva NJ, Rodenburg M, Lawson JS, Inglis J, Waldron JJ, et al. Therapeutic advantage of bifrontal electrode placement in ECT. Psychol Med. May. 1993;23(2):349-60. [pmid: 8332652].
682 Leung M, Hollander Y, Brown GR. Pretreatment with ibuprofen to prevent electroconvulsive therapy-induced headache. J Clin Psychiatry. May. 2003;64(5):551-3. [pmid: 12755658].
683 Levin GM, Bowles TM, Ehret MJ, Langaee T, Tan JY, Johnson JA, et al. Assessment of human serotonin 1A receptor polymorphisms and SSRI responsiveness. Mol Diagn Ther. 2007;11(3):155-60. [pmid: 17570737].
684 Levine J. Controlled trials of inositol in psychiatry. Eur Neuropsychopharmacol. May. 1997;7(2):147-55. [pmid: 9169302].
685 Levine J, Pomerantz T, Stier S, Belmaker RH. Lack of effect of 6 g inositol treatment of post-ECT cognitive function in humans. J Psychiatr Res. Nov-Dec. 1995;29(6):487-9. [pmid: 8642546].
686 Levine J, Swartz M, Feibel H, Schreiber G. Premedication with non-selective and M1-selective muscarinic antagonists before ECT. Isr J Psychiatry Relat Sci. 1993;30(3):179-82. [pmid: 8225935].
687 Levine S. The management of resistant depression. Acta Psychiatr Belg. Mar-Apr. 1986;86(2):141-51. [pmid: 3088916].
688 Levinson AJ, Fitzgerald PB, Favalli G, Blumberger DM, Daigle M, Daskalakis ZJ. Evidence of cortical inhibitory deficits in major depressive disorder. Biol Psychiatry. Mar. 1. 2010;67(5):458-64. [pmid: 19922906].
689 Levitt AJ, Joffe RT, Kennedy SH. Bright light augmentation in antidepressant nonresponders. J Clin Psychiatry. Aug. 1991;52(8):336-7. [pmid: 1869495].
690 Levitt AJ, Wesson VA, Joffe RT. Impact of suppression of thyroxine on folate status during acute antidepressant therapy. Psychiatry Res. Jun. 15. 1998;79(2):123-9. [pmid: 9705050].
691 Levy E, Margolese HC. Migraine headache prophylaxis and treatment with low-dose mirtazapine. Int Clin Psychopharmacol. Sep. 2003;18(5):301-3. [pmid: 12920393].
692 Leykin Y, Amsterdam JD, DeRubeis RJ, Gallop R, Shelton RC, Hollon SD. Progressive resistance to a selective serotonin reuptake inhibitor but not to cognitive therapy in the treatment of major depression. J Consult Clin Psychol. Apr. 2007;75(2):267-76. [pmid: 17469884].
693 Li CT, Lin CP, Chou KH, Chen IY, Hsieh JC, Wu CL, et al. Structural and cognitive deficits in remitting and non-remitting recurrent depression: a voxel-based morphometric study. Neuroimage. Mar. 2010;50(1):347-56. [pmid: 19931620].
694 Li X, Nahas Z, Kozel FA, Anderson B, Bohning DE, George MS. Acute left prefrontal transcranial magnetic stimulation in depressed patients is associated with immediately increased activity in prefrontal cortical as well as subcortical regions. Biol Psychiatry. May. 1. 2004;55(9):882-90. [pmid: 15110731].
695 Li X, Nahas Z, Lomarev M, Denslow S, Shastri A, Bohning DE, et al. Prefrontal cortex transcranial magnetic stimulation does not change local diffusion: a magnetic resonance imaging study in patients with depression. Cogn Behav Neurol. Jun. 2003;16(2):128-35. [pmid: 12799599].
696 Li YS, Meyer JS, Thornby J. Longitudinal follow-up of depressive symptoms among normal versus cognitively impaired elderly. Int J Geriatr Psychiatry. Jul. 2001;16(7):718-27. [pmid: 11466752].
697 Lieb J. Lithium and antidepressants: inhibiting eicosanoids, stimulating immunity, and defeating microorganisms. Med Hypotheses. Oct. 2002;59(4):429-32. [pmid: 12208183].
698 Liebrenz M, Borgeat A, Leisinger R, Stohler R. Intravenous ketamine therapy in a patient with a treatment-resistant major depression. Swiss Med Wkly. Apr. 21. 2007;137(15-16):234-6. [pmid: 17525879].
699 Lisanby SH, Devanand DP, Prudic J, Pierson D, Nobler MS, Fitzsimons L, et al. Prolactin response to electroconvulsive therapy: effects of electrode placement and stimulus dosage. Biol Psychiatry. Jan. 15. 1998;43(2):146-55. [pmid: 9474447].
700 Lisanby SH, Husain MM, Rosenquist PB, Maixner D, Gutierrez R, Krystal A, et al. Daily left prefrontal repetitive transcranial magnetic stimulation in the acute treatment of major depression: clinical predictors of outcome in a multisite, randomized controlled clinical trial. Neuropsychopharmacology. Jan. 2009;34(2):522-34. [pmid: 18704101].
701 Lisanby SH, Maddox JH, Prudic J, Devanand DP, Sackeim HA. The effects of electroconvulsive therapy on memory of autobiographical and public events. Arch Gen Psychiatry. Jun. 2000;57(6):581-90. [pmid: 10839336].
702 Little A. Treatment-resistant depression. Am Fam Physician. Jul. 15. 2009;80(2):167-72. [pmid: 19621857].
703 Little JD. Effect of recommended dosage range on the prescribing of antidepressants. Aust N Z J Psychiatry. Jun. 1995;29(2):304-8. [pmid: 7487796].
704 Little JT, Kimbrell TA, Wassermann EM, Grafman J, Figueras S, Dunn RT, et al. Cognitive effects of 1- and 20-hertz repetitive transcranial magnetic stimulation in depression: preliminary report. Neuropsychiatry Neuropsychol Behav Neurol. Apr. 2000;13(2):119-24. [pmid: 10780630].
705 Liu Z, Zhu F, Wang G, Xiao Z, Tang J, Liu W, et al. Association study of corticotropin-releasing hormone receptor1 gene polymorphisms and antidepressant response in major depressive disorders. Neurosci Lett. Mar. 6. 2007;414(2):155-8. [pmid: 17258395].
706 Locala JA, Irefin SA, Malone D, Cywinski JB, Samuel SW, Naugle R. The comparative hemodynamic effects of methohexital and remifentanil in electroconvulsive therapy. J Ect. Mar. 2005;21(1):12-5. [pmid: 15791171].
707 Loimer N, Hofmann P, Chaudhry HR. Midazolam shortens seizure duration following electroconvulsive therapy. J Psychiatr Res. Apr. 1992;26(2):97-101. [pmid: 1613682].
708 Lojko D, Rybakowski JK. L-thyroxine augmentation of serotonergic antidepressants in female patients with refractory depression. J Affect Disord. Nov. 2007;103(1-3):253-6. [pmid: 17289154].
709 Lomarev M, Denslow S, Nahas Z, Chae JH, George MS, Bohning DE. Vagus nerve stimulation (VNS) synchronized BOLD fMRI suggests that VNS in depressed adults has frequency/dose dependent effects. J Psychiatr Res. Jul-Aug. 2002;36(4):219-27. [pmid: 12191626].
710 Londborg PD, Smith WT, Glaudin V, Painter JR. Short-term cotherapy with clonazepam and fluoxetine: anxiety, sleep disturbance and core symptoms of depression. J Affect Disord. Dec. 2000;61(1-2):73-9. [pmid: 11099743].
711 Loo C, Sachdev P, Elsayed H, McDarmont B, Mitchell P, Wilkinson M, et al. Effects of a 2- to 4-week course of repetitive transcranial magnetic stimulation (rTMS) on neuropsychologic functioning, electroencephalogram, and auditory threshold in depressed patients. Biol Psychiatry. Apr. 1. 2001;49(7):615-23. [pmid: 11297719].
712 Loo CK, McFarquhar TF, Mitchell PB. A review of the safety of repetitive transcranial magnetic stimulation as a clinical treatment for depression. Int J Neuropsychopharmacol. Feb. 2008;11(1):131-47. [pmid: 17880752].
713 Loo CK, Mitchell PB, Croker VM, Malhi GS, Wen W, Gandevia SC, et al. Double-blind controlled investigation of bilateral prefrontal transcranial magnetic stimulation for the treatment of resistant major depression. Psychol Med. Jan. 2003;33(1):33-40. [pmid: 12537034].
714 Loo CK, Mitchell PB, McFarquhar TF, Malhi GS, Sachdev PS. A sham-controlled trial of the efficacy and safety of twice-daily rTMS in major depression. Psychol Med. Mar. 2007;37(3):341-9. [pmid: 17176505].
715 Loo CK, Sachdev P, Mitchell PB, Gandevia SC, Malhi GS, Todd G, et al. A study using transcranial magnetic stimulation to investigate motor mechanisms in psychomotor retardation in depression. Int J Neuropsychopharmacol. Nov. 2008;11(7):935-46. [pmid: 18447965].
716 Loo CK, Sachdev PS, Haindl W, Wen W, Mitchell PB, Croker VM, et al. High (15 Hz) and low (1 Hz) frequency transcranial magnetic stimulation have different acute effects on regional cerebral blood flow in depressed patients. Psychol Med. Aug. 2003;33(6):997-1006. [pmid: 12946084].
717 Lopez-Munoz F, Alamo C, Rubio G, Garcia-Garcia P, Pardo A. Reboxetine combination in treatment-resistant depression to selective serotonin reuptake inhibitors. Pharmacopsychiatry. Jan. 2007;40(1):14-9. [pmid: 17327955].
718 Lopez-Munoz F, Rubio G, Alamo C, Garcia-Garcia P, Pardo A. Reboxetine addition in patients with mirtazapine-resistant depression: a case series. Clin Neuropharmacol. Jul-Aug. 2006;29(4):192-6. [pmid: 16855420].
719 Luber B, Nobler MS, Moeller JR, Katzman GP, Prudic J, Devanand DP, et al. Quantitative EEG during seizures induced by electroconvulsive therapy: relations to treatment modality and clinical features. II. Topographic analyses. J Ect. Sep. 2000;16(3):229-43. [pmid: 11005044].
720 Luborzewski A, Schubert F, Seifert F, Danker-Hopfe H, Brakemeier EL, Schlattmann P, et al. Metabolic alterations in the dorsolateral prefrontal cortex after treatment with high-frequency repetitive transcranial magnetic stimulation in patients with unipolar major depression. J Psychiatr Res. Oct. 2007;41(7):606-15. [pmid: 16600298].
721 Lydiard RB. Tricyclic-resistant depression: treatment resistance or inadequate treatment?. J Clin Psychiatry. Oct. 1985;46(10):412-7. [pmid: 3900051].
722 Lykouras E, Malliaras D, Christodoulou GN, Papakostas Y, Voulgari A, Tzonou A, et al. Delusional depression: phenomenology and response to treatment. A prospective study. Acta Psychiatr Scand. Mar. 1986;73(3):324-9. [pmid: 2872774].
723 Lykouras L, Avgoustides D, Papakostas Y, Stefanis C. Medication response to ECT-resistant melancholic patients. Acta Psychiatr Belg. May-Jun. 1995;95(3):113-21. [pmid: 8525854].
724 Lykouras L, Christodoulou GN, Malliaras D, Stefanis C. The prognostic importance of delusions in depression: a 6-year prospective follow-up study. J Affect Disord. Dec. 1994;32(4):233-8. [pmid: 7897086].
725 Lykouras L, Markianos M, Augoustides A, Papakostas Y, Stefanis C. Evaluation of TSH and prolactin responses to TRH as predictors of the therapeutic effect of ECT in depression. Eur Neuropsychopharmacol. Jun. 1993;3(2):81-3. [pmid: 8364352].
726 Lyon DE, Schubert C, Taylor AG. Pilot study of cranial stimulation for symptom management in breast cancer. Oncol Nurs Forum. Jul. 2010;37(4):476-83. [pmid: 20591807].
727 MacEwan GW, Remick RA. Treatment resistant depression: a clinical perspective. Can J Psychiatry. Dec. 1988;33(9):788-92. [pmid: 3214826].
728 Machado-Vieira R, Yuan P, Brutsche N, DiazGranados N, Luckenbaugh D, Manji HK, et al. Brain-derived neurotrophic factor and initial antidepressant response to an N-methyl-D-aspartate antagonist. J Clin Psychiatry. Dec. 2009;70(12):1662-6. [pmid: 19744406].
729 Maeda F, Keenan JP, Pascual-Leone A. Interhemispheric asymmetry of motor cortical excitability in major depression as measured by transcranial magnetic stimulation. Br J Psychiatry. Aug. 2000;177:169-73. [pmid: 11026958].
730 Maes M, Bosmans E, De Jongh R, Kenis G, Vandoolaeghe E, Neels H. Increased serum IL-6 and IL-1 receptor antagonist concentrations in major depression and treatment resistant depression. Cytokine. Nov. 1997;9(11):853-8. [pmid: 9367546].
731 Maes M, De Meester I, Verkerk R, De Medts P, Wauters A, Vanhoof G, et al. Lower serum dipeptidyl peptidase IV activity in treatment resistant major depression: relationships with immune-inflammatory markers. Psychoneuroendocrinology. Feb. 1997;22(2):65-78. [pmid: 9149329].
732 Maes M, Libbrecht I, van Hunsel F, Campens D, Meltzer HY. Pindolol and mianserin augment the antidepressant activity of fluoxetine in hospitalized major depressed patients, including those with treatment resistance. J Clin Psychopharmacol. Apr. 1999;19(2):177-82. [pmid: 10211920].
733 Maes M, Mihaylova I, Kubera M, Uytterhoeven M, Vrydags N, Bosmans E. Lower plasma Coenzyme Q10 in depression: a marker for treatment resistance and chronic fatigue in depression and a risk factor to cardiovascular disorder in that illness. Neuro Endocrinol Lett. 2009;30(4):462-9. [pmid: 20010493].
734 Maes M, Vandoolaeghe E, Desnyder R. Efficacy of treatment with trazodone in combination with pindolol or fluoxetine in major depression. J Affect Disord. 1996:201-10.
735 Maes M, Vandoolaeghe E, Neels H, Demedts P, Wauters A, Meltzer HY, et al. Lower serum zinc in major depression is a sensitive marker of treatment resistance and of the immune/inflammatory response in that illness. Biol Psychiatry. Sep. 1. 1997;42(5):349-58. [pmid: 9276075].
736 Maes M, Verkerk R, Vandoolaeghe E, Lin A, Scharpe S. Serum levels of excitatory amino acids, serine, glycine, histidine, threonine, taurine, alanine and arginine in treatment-resistant depression: modulation by treatment with antidepressants and prediction of clinical responsivity. Acta Psychiatr Scand. Apr. 1998;97(4):302-8. [pmid: 9570492].
737 Maes M, Verkerk R, Vandoolaeghe E, Van Hunsel F, Neels H, Wauters A, et al. Serotonin-immune interactions in major depression: lower serum tryptophan as a marker of an immune-inflammatory response. Eur Arch Psychiatry Clin Neurosci. 1997;247(3):154-61. [pmid: 9224908].
738 Magni G, Fisman M, Helmes E. Clinical correlates of ECT-resistant depression in the elderly. J Clin Psychiatry. Oct. 1988;49(10):405-7. [pmid: 3170492].
739 Malaspina D, Amador XF, Coleman EA, Mayr TL, Friedman JH, Sackeim HA. Smooth pursuit eye movement abnormality in severe major depression: effects of ECT and clinical recovery. J Neuropsychiatry Clin Neurosci. Winter. 1994;6(1):36-42. [pmid: 8148635].
740 Malaspina D, Devanand DP, Krueger RB, Prudic J, Sackeim HA. The significance of clinical EEG abnormalities in depressed patients treated with ECT. Convuls Ther. Dec. 1994;10(4):259-66. [pmid: 7850395].
741 Malhi GS. Upping the ante on antidepressants. Bipolar Disord. Dec. 2008;10(8):975-8. [pmid: 19594513].
742 Malhi GS, Ng F, Berk M. Dual-dual action? Combining venlafaxine and mirtazapine in the treatment of depression. Aust N Z J Psychiatry. Apr. 2008;42(4):346-9. [pmid: 18330778].
743 Malitz S, Sackeim HA, Decina P, Kanzler M, Kerr B. The efficacy of electroconvulsive therapy. Dose-response interactions with modality. Ann N Y Acad Sci. 1986;462:56-64. [pmid: 3458419].
744 Malsch E, Gratz I, Mani S, Backup C, Levy S, Allen E. Efficacy of electroconvulsive therapy after propofol and methohexital anesthesia. Convuls Ther. Sep. 1994;10(3):212-9. [pmid: 7834258].
745 Manji HK, Quiroz JA, Sporn J, Payne JL, Denicoff K, N AG, et al. Enhancing neuronal plasticity and cellular resilience to develop novel, improved therapeutics for difficult-to-treat depression. Biol Psychiatry. Apr. 15. 2003;53(8):707-42. [pmid: 12706957].
746 Manning JS. What alternatives to first-line therapy for depression are effective?. J Clin Psychiatry. 1. 2010;71:10-5. [pmid: 20977870].
747 Manning JS, Haykal RF, Connor PD, Cunningham PD, Jackson WC, Long S. Sustained remission with lamotrigine augmentation or monotherapy in female resistant depressives with mixed cyclothymic-dysthymic temperament. J Affect Disord. Feb. 2005;84(2-3):259-66. [pmid: 15708424].
748 Marangell LB. Augmentation of standard depression therapy. Clin Ther. A. 2000;22:A25-38. discussion A9-41. [pmid: 10815648].
749 Marangell LB. Switching antidepressants for treatment-resistant major depression. J Clin Psychiatry. 18. 2001;62:12-7. [pmid: 11575730].
750 Marangell LB, Rush AJ, George MS, Sackeim HA, Johnson CR, Husain MM, et al. Vagus nerve stimulation (VNS) for major depressive episodes: one year outcomes. Biol Psychiatry. Feb. 15. 2002;51(4):280-7. [pmid: 11958778].
751 Marano CM, Phatak P, Vemulapalli UR, Sasan A, Nalbandyan MR, Ramanujam S, et al. Increased plasma concentration of brain-derived neurotrophic factor with electroconvulsive therapy: a pilot study in patients with major depression. J Clin Psychiatry. Apr. 2007;68(4):512-7. [pmid: 17474805].
752 Marco EJ, Wolkowitz OM, Vinogradov S, Poole JH, Lichtmacher J, Reus VI. Double-blind antiglucocorticoid treatment in schizophrenia and schizoaffective disorder: a pilot study. World J Biol Psychiatry. Jul. 2002;3(3):156-61. [pmid: 12478881].
753 Markianos M, Hatzimanolis J, Lykouras L. Serotonergic and dopaminergic neuroendocrine responses of male depressive patients before and after a therapeutic ECT course. Eur Arch Psychiatry Clin Neurosci. Aug. 2002;252(4):172-6. [pmid: 12242578].
754 Markianos M, Hatzimanolis J, Lykouras L. Relationship between prolactin responses to ECT and dopaminergic and serotonergic responsivity in depressed patients. Eur Arch Psychiatry Clin Neurosci. Aug. 2002;252(4):166-71. [pmid: 12242577].
755 Markopoulou K, Papadopoulos A, Juruena MF, Poon L, Pariante CM, Cleare AJ. The ratio of cortisol/DHEA in treatment resistant depression. Psychoneuroendocrinology. Jan. 2009;34(1):19-26. [pmid: 18805642].
756 Martensson B, Bartfai A, Hallen B, Hellstrom C, Junthe T, Olander M. A comparison of propofol and methohexital as anesthetic agents for ECT: effects on seizure duration, therapeutic outcome, and memory. Biol Psychiatry. Feb. 1. 1994;35(3):179-89. [pmid: 8173018].
757 Martin JL, Barbanoj MJ, Schlaepfer TE, Thompson E, Perez V, Kulisevsky J. Repetitive transcranial magnetic stimulation for the treatment of depression. Systematic review and meta-analysis. Br J Psychiatry. Jun. 2003;182:480-91. [pmid: 12777338].
758 Martiny K, Lunde M, Bech P. Transcranial low voltage pulsed electromagnetic fields in patients with treatment-resistant depression. Biol Psychiatry. Jul. 15. 2010;68(2):163-9. [pmid: 20385376].
759 Martis B, Alam D, Dowd SM, Hill SK, Sharma RP, Rosen C, et al. Neurocognitive effects of repetitive transcranial magnetic stimulation in severe major depression. Clin Neurophysiol. Jun. 2003;114(6):1125-32. [pmid: 12804681].
760 Masand PS, Gupta S. Selective serotonin-reuptake inhibitors: an update. Harv Rev Psychiatry. Jul-Aug. 1999;7(2):69-84. [pmid: 10471245].
761 Mathew SJ. Treatment-resistant depression: recent developments and future directions. Depress Anxiety. 2008;25(12):989-92. [pmid: 19058261].
762 Matsunaga M, Okamoto Y, Suzuki S, Kinoshita A, Yoshimura S, Yoshino A, et al. Psychosocial functioning in patients with Treatment-Resistant Depression after group cognitive behavioral therapy. BMC Psychiatry. 2010;10:22. [pmid: 20230649].
763 Matsura MJ, Fujiwara Y, Ito H, Kandatsu N, Kato N, Harada J, et al. Prolongation of QT interval induced by electroconvulsive therapy is attenuated by landiolol. J ECT. Mar. 2010;26(1):37-40. [pmid: 20190601].
764 Matters RM, Beckett WG, Kirkby KC, King TE. Recovery after electroconvulsive therapy: comparison of propofol with methohexitone anaesthesia. Br J Anaesth. Sep. 1995;75(3):297-300. [pmid: 7547047].
765 Mattes JA. Pergolide to augment the effectiveness of antidepressants: clinical experience and a small double-blind study. Ann Clin Psychiatry. Jun. 1997;9(2):87-8. [pmid: 9242894].
766 Mattes JA, Pettinati HM, Nilsen SM, Robin SE, Willis KW. Vasopressin for ECT-induced memory impairment: a placebo-controlled comparison. Psychopharmacol Bull. 1989;25(1):80-4. [pmid: 2772120].
767 Mattes JA, Pettinati HM, Stephens S, Robin SE, Willis KW. A placebo-controlled evaluation of vasopressin for ECT-induced memory impairment. Biol Psychiatry. Feb. 1. 1990;27(3):289-303. [pmid: 2405915].
768 Mayberg HS. Targeted electrode-based modulation of neural circuits for depression. J Clin Invest. Apr. 2009;119(4):717-25. [pmid: 19339763].
769 Mayberg HS, Lozano AM, Voon V, McNeely HE, Seminowicz D, Hamani C, et al. Deep brain stimulation for treatment-resistant depression. Neuron. Mar. 3. 2005;45(5):651-60. [pmid: 15748841].
770 Mayur P, Bray A, Fernandes J, Bythe K, Gilbett D. Impact of hyperventilation on stimulus efficiency during the early phase of an electroconvulsive therapy course: a randomized double-blind study. J ECT. Jun. 2010;26(2):91-4. [pmid: 20514695].
771 Mayur PM, Gangadhar BN, Subbakrishna DK, Janakiramaiah N. Discontinuation of antidepressant drugs during electroconvulsive therapy: a controlled study. J Affect Disord. Apr. 2000;58(1):37-41. [pmid: 10760556].
772 Mazeh D, Shahal B, Aviv A, Zemishlani H, Barak Y. A randomized, single-blind, comparison of venlafaxine with paroxetine in elderly patients suffering from resistant depression. Int Clin Psychopharmacol. 2007:371-5.
773 Mazella J, Petrault O, Lucas G, Deval E, Beraud-Dufour S, Gandin C, et al. Spadin, a sortilin-derived peptide, targeting rodent TREK-1 channels: a new concept in the antidepressant drug design. PLoS Biol. 2010;8(4):e1000355. [pmid: 20405001].
774 McCall WV, Colenda CC, Farah BA. Ictal EEG regularity declines during a course of RUL ECT. Convuls Ther. Dec. 1996;12(4):213-6. [pmid: 9034695].
775 McCall WV, Dunn A, Rosenquist PB. Quality of life and function after electroconvulsive therapy. Br J Psychiatry. Nov. 2004;185:405-9. [pmid: 15516549].
776 McCall WV, Dunn A, Rosenquist PB, Hughes D. Markedly suprathreshold right unilateral ECT versus minimally suprathreshold bilateral ECT: antidepressant and memory effects. J Ect. Sep. 2002;18(3):126-9. [pmid: 12394530].
777 McCall WV, Dunn AG, Rosenquist P, Hughes D. Proxy validation of patient self-reports of ADL and IADL function before and after electroconvulsive therapy. J Ect. Jun. 2002;18(2):74-9. [pmid: 12195134].
778 McCall WV, Prudic J, Olfson M, Sackeim H. Health-related quality of life following ECT in a large community sample. J Affect Disord. Feb. 2006;90(2-3):269-74. [pmid: 16412519].
779 McCall WV, Reboussin BA, Cohen W, Lawton P. Electroconvulsive therapy is associated with superior symptomatic and functional change in depressed patients after psychiatric hospitalization. J Affect Disord. Mar. 2001;63(1-3):17-25. [pmid: 11246076].
780 McCall WV, Reboussin DM, Weiner RD, Sackeim HA. Titrated moderately suprathreshold vs fixed high-dose right unilateral electroconvulsive therapy: acute antidepressant and cognitive effects. Arch Gen Psychiatry. May. 2000;57(5):438-44. [pmid: 10807483].
781 McCall WV, Shelp FE, Weiner RD, Austin S, Norris J. Convulsive threshold differences in right unilateral and bilateral ECT. Biol Psychiatry. Nov. 1. 1993;34(9):606-11. [pmid: 8292689].
782 McCall WV, Zvara D, Brooker R, Arias L. Effect of esmolol pretreatment on EEG seizure morphology in RUL ECT. Convuls Ther. Sep. 1997;13(3):175-80. [pmid: 9342133].
783 McCombs J. Managing antidepressant drug therapy in an evolving marketplace. Am J Manag Care. Jul. 2004;10(6 Suppl):S173-8. [pmid: 15354674].
784 McCormick LM, Yamada T, Yeh M, Brumm MC, Thatcher RW. Antipsychotic effect of electroconvulsive therapy is related to normalization of subgenual cingulate theta activity in psychotic depression. J Psychiatr Res. Feb. 2009;43(5):553-60. [pmid: 18851858].
785 McDonald WM. Is ECT cost-effective? A critique of the National Institute of Health and Clinical Excellence's report on the economic analysis of ECT. J Ect. Mar. 2006;22(1):25-9. [pmid: 16633202].
786 McDougle CJ, Goodman WK, Leckman JF, Holzer JC, Barr LC, McCance-Katz E, et al. Limited therapeutic effect of addition of buspirone in fluvoxamine-refractory obsessive-compulsive disorder. Am J Psychiatry. Apr. 1993;150(4):647-9. [pmid: 8465885].
787 McGrath PJ, Stewart JW, Fava M, Trivedi MH, Wisniewski SR, Nierenberg AA, et al. Tranylcypromine versus venlafaxine plus mirtazapine following three failed antidepressant medication trials for depression: a STAR*D report. Am J Psychiatry. 2006:1531-41. quiz 666.
788 McGrath PJ, Stewart JW, Nunes EN, Quitkin FM. Treatment response of depressed outpatients unresponsive to both a tricyclic and a monoamine oxidase inhibitor antidepressant. J Clin Psychiatry. Aug. 1994;55(8):336-9. [pmid: 8071301].
789 McGrath PJ, Stewart JW, Nunes EV, Ocepek-Welikson K, Rabkin JG, Quitkin FM, et al. A double-blind crossover trial of imipramine and phenelzine for outpatients with treatment-refractory depression. Am J Psychiatry. Jan. 1993;150(1):118-23. [pmid: 8417553].
790 McGrath PJ, Stewart JW, Quitkin FM, Chen Y, Alpert JE, Nierenberg AA, et al. Predictors of relapse in a prospective study of fluoxetine treatment of major depression. Am J Psychiatry. Sep. 2006;163(9):1542-8. [pmid: 16946178].
791 McIntyre J, Moral MA. Spotlight on lamotrigine for depression. Drug News Perspect. Sep. 2006;19(7):427-30. [pmid: 17080205].
792 McIntyre RS, Muller A, Mancini DA, Silver ES. What to do if an initial antidepressant fails?. Can Fam Physician. Apr. 2003;49:449-57. [pmid: 12729241].
793 McIntyre RS, Soczynska JK, Konarski JZ, Kennedy SH. The effect of antidepressants on glucose homeostasis and insulin sensitivity: synthesis and mechanisms. Expert Opin Drug Saf. Jan. 2006;5(1):157-68. [pmid: 16370964].
794 McLoughlin DM. Vagus rules still apply. Psychol Med. May. 2008;38(5):625-7. [pmid: 18494108].
795 McLoughlin DM, Mogg A, Eranti S, Pluck G, Purvis R, Edwards D, et al. The clinical effectiveness and cost of repetitive transcranial magnetic stimulation versus electroconvulsive therapy in severe depression: a multicentre pragmatic randomised controlled trial and economic analysis. Health Technol Assess. Jul. 2007;11(24):1-54. [pmid: 17580003].
796 McPherson S, Cairns P, Carlyle J, Shapiro DA, Richardson P, Taylor D. The effectiveness of psychological treatments for treatment-resistant depression: a systematic review. Acta Psychiatr Scand. May. 2005;111(5):331-40. [pmid: 15819726].
797 Meats P, Timol M, Jolley D. Prognosis of depression in the elderly. Br J Psychiatry. Nov. 1991;159:659-63. [pmid: 1756342].
798 Meeks S, Looney SW, Van Haitsma K, Teri L. BE-ACTIV: a staff-assisted behavioral intervention for depression in nursing homes. Gerontologist. Feb. 2008;48(1):105-14. [pmid: 18381837].
799 Melfi CA, Chawla AJ, Croghan TW, Hanna MP, Kennedy S, Sredl K. The effects of adherence to antidepressant treatment guidelines on relapse and recurrence of depression. Arch Gen Psychiatry. Dec. 1998;55(12):1128-32. [pmid: 9862557].
800 Mendlewicz J, Hubain PP, Koumakis C. Further investigation of the dexamethasone suppression test in affective illnesses: relationship to clinical diagnosis and therapeutic response. Neuropsychobiology. 1984;12(1):23-6. [pmid: 6514175].
801 Mendlewicz J, Kriwin P, Oswald P, Souery D, Alboni S, Brunello N. Shortened onset of action of antidepressants in major depression using acetylsalicylic acid augmentation: a pilot open-label study. Int Clin Psychopharmacol. Jul. 2006;21(4):227-31. [pmid: 16687994].
802 Merrill CA, Jonsson MA, Minthon L, Ejnell H, CsS H, Blennow K, et al. Vagus nerve stimulation in patients with Alzheimer's disease: Additional follow-up results of a pilot study through 1 year. J Clin Psychiatry. Aug. 2006;67(8):1171-8. [pmid: 16965193].
803 Mervaala E, Fohr J, Kononen M, Valkonen-Korhonen M, Vainio P, Partanen K, et al. Quantitative MRI of the hippocampus and amygdala in severe depression. Psychol Med. Jan. 2000;30(1):117-25. [pmid: 10722182].
804 Metcalf G. Regulatory peptides as a source of new drugs--the clinical prospects for analogues of TRH which are resistant to metabolic degradation. Brain Res. Nov. 1982;257(3):389-408. [pmid: 6816389].
805 Meterissian GB, Bradwejn J. Comparative studies on the efficacy of psychotherapy, pharmacotherapy, and their combination in depression: was adequate pharmacotherapy provided?. J Clin Psychopharmacol. Oct. 1989;9(5):334-9. [pmid: 2677061].
806 Meyers BS, Klimstra SA, Gabriele M, Hamilton M, Kakuma T, Tirumalasetti F, et al. Continuation treatment of delusional depression in older adults. Am J Geriatr Psychiatry. Fall. 2001;9(4):415-22. [pmid: 11739068].
807 Meyers BS, Mei-Tal V. Empirical study on an inpatient psychogeriatric unit: biological treatment in patients with depressive illness. Int J Psychiatry Med. 1985;15(2):111-24. [pmid: 2865228].
808 Michael N, Erfurth A, Ohrmann P, Arolt V, Heindel W, Pfleiderer B. Neurotrophic effects of electroconvulsive therapy: a proton magnetic resonance study of the left amygdalar region in patients with treatment-resistant depression. Neuropsychopharmacology. Apr. 2003;28(4):720-5. [pmid: 12655317].
809 Michalak EE, Lam RW. Breaking the myths: new treatment approaches for chronic depression. Can J Psychiatry. Sep. 2002;47(7):635-43. [pmid: 12355675].
810 Michelson D, Adler LA, Amsterdam JD, Dunner DL, Nierenberg AA, Reimherr FW, et al. Addition of atomoxetine for depression incompletely responsive to sertraline: a randomized, double-blind, placebo-controlled study. J Clin Psychiatry. Apr. 2007;68(4):582-7. [pmid: 17474814].
811 Mihaljevic-Peles A, Sagud M, Bozina N, Zivkovic M. Pharamacogenetics and antidepressant treatment in integrative psychiatry perspective. Psychiatr Danub. Sep. 2008;20(3):399-401. [pmid: 18827770].
812 Milev R, Abraham G, Hasey G, Cabaj JL. Repetitive transcranial magnetic stimulation for treatment of medication-resistant depression in older adults: a case series. J Ect. Mar. 2009;25(1):44-9. [pmid: 18665102].
813 Miller KK, Perlis RH, Papakostas GI, Mischoulon D, Losifescu DV, Brick DJ, et al. Low-dose transdermal testosterone augmentation therapy improves depression severity in women. CNS Spectr. Dec. 2009;14(12):688-94. [pmid: 20394176].
814 Miller MD, Lenze EJ, Dew MA, Whyte E, Weber E, Begley AE, et al. Effect of cerebrovascular risk factors on depression treatment outcome in later life. Am J Geriatr Psychiatry. Sep-Oct. 2002;10(5):592-8. [pmid: 12213694].
815 Miniussi C, Bonato C, Bignotti S, Gazzoli A, Gennarelli M, Pasqualetti P, et al. Repetitive transcranial magnetic stimulation (rTMS) at high and low frequency: an efficacious therapy for major drug-resistant depression?. Clin Neurophysiol. May. 2005;116(5):1062-71. [pmid: 15826846].
816 Mischoulon D, Nierenberg AA, Kizilbash L, Rosenbaum JF, Fava M. Strategies for managing depression refractory to selective serotonin reuptake inhibitor treatment: a survey of clinicians. Can J Psychiatry. Jun. 2000;45(5):476-81. [pmid: 10900529].
817 Mitchell AJ, Subramaniam H. Prognosis of depression in old age compared to middle age: a systematic review of comparative studies. Am J Psychiatry. Sep. 2005;162(9):1588-601. [pmid: 16135616].
818 Mitchell P. The pharmacological treatment of tricyclic-resistant depression: review and management guidelines. Aust N Z J Psychiatry. Dec. 1987;21(4):442-51. [pmid: 3329512].
819 Mitchell P, Smythe G, Torda T. Effect of the anesthetic agent propofol on hormonal responses to ECT. Biol Psychiatry. Aug. 15. 1990;28(4):315-24. [pmid: 2168761].
820 Mitchell PB, Schweitzer I, Burrows G, Johnson G, Polonowita A. Efficacy of venlafaxine and predictors of response in a prospective open-label study of patients with treatment-resistant major depression. J Clin Psychopharmacol. Aug. 2000;20(4):483-7. [pmid: 10917411].
821 Mogg A, Purvis R, Eranti S, Contell F, Taylor JP, Nicholson T, et al. Repetitive transcranial magnetic stimulation for negative symptoms of schizophrenia: a randomized controlled pilot study. Schizophr Res. Jul. 2007;93(1-3):221-8. [pmid: 17478080].
822 Moller AL, Hjaltason O, Ivarsson O, Stefansson SB. The effects of repetitive transcranial magnetic stimulation on depressive symptoms and the P(300) event-related potential. Nord J Psychiatry. 2006;60(4):282-5. [pmid: 16923636].
823 Moller HJ. Non-response to antidepressants: risk factors and therapeutic possibilities. Int Clin Psychopharmacol. Jun. 2. 1994;9:17-23. [pmid: 7930492].
824 Moller HJ, Kissling W, Baumann P, Breyer-Pfaff U, Delini-Stula A, Holsboer F, et al. Non-response to antidepressants: risk factors and therapeutic possibilities. Pharmacopsychiatry. Nov. 1988;21(6):285-7. [pmid: 3244754].
825 Moller HJ, Kissling W, Bottermann P. Serial application of clonidine tests during antidepressive treatment with chlorimipramine. Pharmacopsychiatry. Nov. 1984;17(6):184-7. [pmid: 6514781].
826 Moller HJ, Volz HP. Drug treatment of depression in the 1990s. An overview of achievements and future possibilities. Drugs. Nov. 1996;52(5):625-38. [pmid: 9118813].
827 Montgomery SA. New antidepressants and 5-HT uptake inhibitors. Acta Psychiatr Scand Suppl. 1989;350:107-16. [pmid: 2530760].
828 Moreno DH, Moreno RA, Calil HM. A Brazilian experience of treatment-resistant depression. Int Clin Psychopharmacol. Jun. 2. 1994;9:11-6. [pmid: 7930491].
829 Morishita S. Clonazepam as a therapeutic adjunct to improve the management of depression: a brief review. Hum Psychopharmacol. Apr. 2009;24(3):191-8. [pmid: 19330803].
830 Morris DW, Trivedi MH, Rush AJ. Folate and unipolar depression. J Altern Complement Med. Apr. 2008;14(3):277-85. [pmid: 18370582].
831 Morrissey JP, Steadman HJ, Burton NM. A profile of ACT recipients in New York State during 1972 and 1977. Am J Psychiatry. May. 1981;138(5):618-22. [pmid: 7235056].
832 Mosimann UP, Schmitt W, Greenberg BD, Kosel M, Muri RM, Berkhoff M, et al. Repetitive transcranial magnetic stimulation: a putative add-on treatment for major depression in elderly patients. Psychiatry Res. Apr. 30. 2004;126(2):123-33. [pmid: 15123391].
833 Mu Q, Bohning DE, Nahas Z, Walker J, Anderson B, Johnson KA, et al. Acute vagus nerve stimulation using different pulse widths produces varying brain effects. Biol Psychiatry. Apr. 15. 2004;55(8):816-25. [pmid: 15050863].
834 Mueller TI, Leon AC, Keller MB, Solomon DA, Endicott J, Coryell W, et al. Recurrence after recovery from major depressive disorder during 15 years of observational follow-up. Am J Psychiatry. Jul. 1999;156(7):1000-6. [pmid: 10401442].
835 Muller H, Seifert F, Weigel D, Garlichs C, Asemann R, Fluh G, et al. Vagus-nerve stimulation is tolerated in a patient with cardiac AV-Blocks. Prog Neuropsychopharmacol Biol Psychiatry. Aug. 16. 2010;34(6):1150. [pmid: 20677368].
836 Mulsant BH, Haskett RF, Prudic J, Thase ME, Malone KM, Mann JJ, et al. Low use of neuroleptic drugs in the treatment of psychotic major depression. Am J Psychiatry. Apr. 1997;154(4):559-61. [pmid: 9090348].
837 Mulsant BH, Pollock BG. Treatment-resistant depression in late life. J Geriatr Psychiatry Neurol. Winter. 1998;11(4):186-93. [pmid: 10230997].
838 Mulsant BH, Rosen J, Thornton JE, Zubenko GS. A prospective naturalistic study of electroconvulsive therapy in late-life depression. J Geriatr Psychiatry Neurol. Jan-Mar. 1991;4(1):3-13. [pmid: 2054049].
839 Murck H, Song C, Horrobin DF, Uhr M. Ethyl-eicosapentaenoate and dexamethasone resistance in therapy-refractory depression. Int J Neuropsychopharmacol. Sep. 2004;7(3):341-9. [pmid: 15003146].
840 Murphy BE. Antiglucocorticoid therapies in major depression: a review. Psychoneuroendocrinology. 1. 1997;22:S125-32. [pmid: 9264159].
841 Murphy BE, Dhar V, Ghadirian AM, Chouinard G, Keller R. Response to steroid suppression in major depression resistant to antidepressant therapy. J Clin Psychopharmacol. Apr. 1991;11(2):121-6. [pmid: 1829098].
842 Murphy BE, Ghadirian AM, Dhar V. Neuroendocrine responses to inhibitors of steroid biosynthesis in patients with major depression resistant to antidepressant therapy. Can J Psychiatry. Apr. 1998;43(3):279-86. [pmid: 9561317].
843 Murthy PJ, Gangadhar BN, Janakiramaiah N, Subbakrishna DK. Normalization of P300 amplitude following treatment in dysthymia. Biol Psychiatry. Oct. 15. 1997;42(8):740-3. [pmid: 9325569].
844 Myers DH. A questionnaire study of patients' experience of electroconvulsive therapy. J Ect. Sep. 2007;23(3):169-74. [pmid: 17804991].
845 Nadeau SE, McCoy KJ, Crucian GP, Greer RA, Rossi F, Bowers D, et al. Cerebral blood flow changes in depressed patients after treatment with repetitive transcranial magnetic stimulation: evidence of individual variability. Neuropsychiatry Neuropsychol Behav Neurol. Sep. 2002;15(3):159-75. [pmid: 12218709].
846 Nahas Z, DeBrux C, Chandler V, Lorberbaum JP, Speer AM, Molloy MA, et al. Lack of significant changes on magnetic resonance scans before and after 2 weeks of daily left prefrontal repetitive transcranial magnetic stimulation for depression. J Ect. Dec. 2000;16(4):380-90. [pmid: 11314876].
847 Nahas Z, Kunik ME, Orengo CA, Molinari V, Workman R. Depression in male geropsychiatric inpatients with and without dementia: a naturalistic study. J Affect Disord. Dec. 1997;46(3):243-6. [pmid: 9547120].
848 Nahas Z, Li X, Kozel FA, Mirzki D, Memon M, Miller K, et al. Safety and benefits of distance-adjusted prefrontal transcranial magnetic stimulation in depressed patients 55-75 years of age: a pilot study. Depress Anxiety. 2004;19(4):249-56. [pmid: 15274174].
849 Nahas Z, Marangell LB, Husain MM, Rush AJ, Sackeim HA, Lisanby SH, et al. Two-year outcome of vagus nerve stimulation (VNS) for treatment of major depressive episodes. J Clin Psychiatry. Sep. 2005;66(9):1097-104. [pmid: 16187765].
850 Naish JH, Baldwin RC, Patankar T, Jeffries S, Burns AS, Taylor CJ, et al. Abnormalities of CSF flow patterns in the cerebral aqueduct in treatment-resistant late-life depression: a potential biomarker of microvascular angiopathy. Magn Reson Med. Sep. 2006;56(3):509-16. [pmid: 16894588].
851 Nakajima S, Suzuki T, Watanabe K, Kashima H, Uchida H. Accelerating response to antidepressant treatment in depression: a review and clinical suggestions. Prog Neuropsychopharmacol Biol Psychiatry. Mar. 17. 2010;34(2):259-64. [pmid: 19969039].
852 Narushima K, McCormick LM, Yamada T, Thatcher RW, Robinson RG. Subgenual cingulate theta activity predicts treatment response of repetitive transcranial magnetic stimulation in participants with vascular depression. J Neuropsychiatry Clin Neurosci. 2010/02/18. 2010:75-84.
853 Navarro R, Zarkowski P, Sporn A, Avery D. Hemispheric asymmetry in resting motor threshold in major depression. J Ect. Mar. 2009;25(1):39-43. [pmid: 18580815].
854 Navarro V, Gasto C, Lomena F, Mateos JJ, Portella MJ, Masana G, et al. No brain perfusion impairment at long-term follow-up in elderly patients treated with electroconvulsive therapy for major depression. J Ect. Jun. 2004;20(2):89-93. [pmid: 15167424].
855 Navarro V, Gasto C, Lomena F, Mateos JJ, Portella MJ, Massana G, et al. Frontal cerebral perfusion after antidepressant drug treatment versus ECT in elderly patients with major depression: a 12-month follow-up control study. J Clin Psychiatry. May. 2004;65(5):656-61. [pmid: 15163251].
856 Navarro V, Gasto C, Torres X, Masana G, Penades R, Guarch J, et al. Continuation/maintenance treatment with nortriptyline versus combined nortriptyline and ECT in late-life psychotic depression: a two-year randomized study. Am J Geriatr Psychiatry. Jun. 2008;16(6):498-505. [pmid: 18515694].
857 Nelsen MR, Dunner DL. Treatment resistance in unipolar depression and other disorders. Diagnostic concerns and treatment possibilities. Psychiatr Clin North Am. Sep. 1993;16(3):541-66. [pmid: 8415236].
858 Nelsen MR, Dunner DL. Clinical and differential diagnostic aspects of treatment-resistant depression. J Psychiatr Res. Jan-Feb. 1995;29(1):43-50. [pmid: 7629754].
859 Nelson JC. Combined treatment strategies in psychiatry. J Clin Psychiatry. Sep. Suppl. 1993;54:42-9. discussion 55-6. [pmid: 8104933].
860 Nelson JC. Treatment of refractory depression. Depress Anxiety. 1997;5(4):165-74. [pmid: 9338109].
861 Nelson JC. Overcoming treatment resistance in depression. J Clin Psychiatry. 16. 1998;59:13-9. discussion 40-2. [pmid: 9796861].
862 Nelson JC. Augmentation strategies with serotonergic-noradrenergic combinations. J Clin Psychiatry. 5. 1998;59:65-8. discussion 9. [pmid: 9635550].
863 Nelson JC. Augmentation strategies in depression 2000. J Clin Psychiatry. 2. 2000;61:13-9. [pmid: 10714619].
864 Nelson JC. Managing treatment-resistant major depression. J Clin Psychiatry. 1. 2003;64:5-12. [pmid: 12625799].
865 Nelson JC. Augmentation and combination strategies in resistant depression. J Clin Psychiatry. Jun. 2009;70(6):e20. [pmid: 19573476].
866 Nelson JC, Mazure CM, Jatlow PI. Characteristics of desipramine-refractory depression. J Clin Psychiatry. Jan. 1994;55(1):12-9. [pmid: 8294386].
867 Nelson JC, Mazure CM, Jatlow PI, Bowers MB Jr, Price LH. Combining norepinephrine and serotonin reuptake inhibition mechanisms for treatment of depression: a double-blind, randomized study. Biol Psychiatry. Feb. 1. 2004;55(3):296-300. [pmid: 14744472].
868 Nemeroff CB. The clinical pharmacology and use of paroxetine, a new selective serotonin reuptake inhibitor. Pharmacotherapy. Mar-Apr. 1994;14(2):127-38. [pmid: 8197030].
869 Nemeroff CB. Augmentation strategies in patients with refractory depression. Depress Anxiety. 1996;4(4):169-81. [pmid: 9166649].
870 Nemeroff CB. Use of atypical antipsychotics in refractory depression and anxiety. J Clin Psychiatry. 8. 2005;66:13-21. [pmid: 16336032].
871 Nemeroff CB. Prevalence and management of treatment-resistant depression. J Clin Psychiatry. 8. 2007;68:17-25. [pmid: 17640154].
872 Nemeroff CB, Evans DL. Correlation between the dexamethasone suppression test in depressed patients and clinical response. Am J Psychiatry. Feb. 1984;141(2):247-9. [pmid: 6691487].
873 Nemeroff CB, Owens MJ. Treatment of mood disorders. Nat Neurosci. Nov. Suppl. 2002;5:1068-70. [pmid: 12403988].
874 Nemiah JC. Introduction. Part II. When patients don't respond: clinical strategies for managing refractory anxiety and depression. J Clin Psychiatry. Feb. Suppl. 1994;55:18-9. [pmid: 7915711].
875 Neu P, Heuser I, Bajbouj M. Cerebral blood flow during vagus nerve stimulation--a transcranial Doppler study. Neuropsychobiology. 2005;51(4):265-8. [pmid: 15905632].
876 Neuhaus AH, Gallinat J, Bajbouj M, Reischies FM. Interictal slow-wave focus in left medial temporal lobe during bilateral electroconvulsive therapy. Neuropsychobiology. 2005;52(4):183-9. [pmid: 16220024].
877 Neuhaus AH, Luborzewski A, Rentzsch J, Brakemeier EL, Opgen-Rhein C, Gallinat J, et al. P300 is enhanced in responders to vagus nerve stimulation for treatment of major depressive disorder. J Affect Disord. Jun. 2007;100(1-3):123-8. [pmid: 17098290].
878 Nierenberg AA. Treatment choice after one antidepressant fails: a survey of northeastern psychiatrists. J Clin Psychiatry. Sep. 1991;52(9):383-5. [pmid: 1910035].
879 Nierenberg AA, DeCecco LM. Definitions of antidepressant treatment response, remission, nonresponse, partial response, and other relevant outcomes: a focus on treatment-resistant depression. J Clin Psychiatry. 16. 2001;62:5-9. [pmid: 11480882].
880 Nierenberg AA, Dougherty D, Rosenbaum JF. Dopaminergic agents and stimulants as antidepressant augmentation strategies. J Clin Psychiatry. 5. 1998;59:60-3. discussion 4. [pmid: 9635549].
881 Nierenberg AA, Katz J, Fava M. A critical overview of the pharmacologic management of treatment-resistant depression. Psychiatr Clin North Am. Mar. 2007;30(1):13-29. [pmid: 17362800].
882 Nierenberg AA, McColl RD. Management options for refractory depression. Am J Med. Dec. 30. 1996;101(6A):45S-52S. [pmid: 9012610].
883 Nierenberg AA, Ostacher MJ, Calabrese JR, Ketter TA, Marangell LB, Miklowitz DJ, et al. Treatment-resistant bipolar depression: a STEP-BD equipoise randomized effectiveness trial of antidepressant augmentation with lamotrigine, inositol, or risperidone. Am J Psychiatry. Feb. 2006;163(2):210-6. [pmid: 16449473].
884 Nierenberg AA, Ostacher MJ, Huffman JC, Ametrano RM, Fava M, Perlis RH. A brief review of antidepressant efficacy, effectiveness, indications, and usage for major depressive disorder. J Occup Environ Med. Apr. 2008;50(4):428-36. [pmid: 18404015].
885 Nierenberg AA, Price LH, Charney DS, Heninger GR. After lithium augmentation: a retrospective follow-up of patients with antidepressant-refractory depression. J Affect Disord. Mar. 1990;18(3):167-75. [pmid: 2139061].
886 Nikisch G, Mathe AA. CSF monoamine metabolites and neuropeptides in depressed patients before and after electroconvulsive therapy. Eur Psychiatry. Aug. 2008;23(5):356-9. [pmid: 18455913].
887 Nishihara F, Saito S. Adjustment of anaesthesia depth using bispectral index prolongs seizure duration in electroconvulsive therapy. Anaesth Intensive Care. Oct. 2004;32(5):661-5. [pmid: 15535490].
888 Nobler MS, Luber B, Moeller JR, Katzman GP, Prudic J, Devanand DP, et al. Quantitative EEG during seizures induced by electroconvulsive therapy: relations to treatment modality and clinical features. I. Global analyses. J Ect. Sep. 2000;16(3):211-28. [pmid: 11005043].
889 Nobler MS, Oquendo MA, Kegeles LS, Malone KM, Campbell CC, Sackeim HA, et al. Decreased regional brain metabolism after ect. Am J Psychiatry. Feb. 2001;158(2):305-8. [pmid: 11156816].
890 Nobler MS, Sackeim HA, Moeller JR, Prudic J, Petkova E, Waternaux C. Quantifying the speed of symptomatic improvement with electroconvulsive therapy: comparison of alternative statistical methods. Convuls Ther. Dec. 1997;13(4):208-21. [pmid: 9437565].
891 Nolen WA. Tranylcypromine in depression resistant to cyclic antidepressions. Prog Neuropsychopharmacol Biol Psychiatry. 1989;13(1-2):155-8. [pmid: 2664883].
892 Nolen WA, Bloemkolk D. Treatment of bipolar depression, a review of the literature and a suggestion for an algorithm. Neuropsychobiology. 1. 2000;42:11-7. [pmid: 11093064].
893 Nolen WA, Haffmans PM, Bouvy PF, Duivenvoorden HJ. Monoamine oxidase inhibitors in resistant major depression. A double-blind comparison of brofaromine and tranylcypromine in patients resistant to tricyclic antidepressants. J Affect Disord. Jul. 1993;28(3):189-97. [pmid: 8408980].
894 Nolen WA, Hoencamp E, Bouvy PF, Haffmans PM. Reversible monoamine oxidase-A inhibitors in resistant major depression. Clin Neuropharmacol. 2. 1993;16:S69-76. [pmid: 8313400].
895 Nolen WA, van de Putte JJ, Dijken WA, Kamp JS. L-5HTP in depression resistant to re-uptake inhibitors. An open comparative study with tranylcypromine. Br J Psychiatry. Jul. 1985;147:16-22. [pmid: 3933601].
896 Nolen WA, van de Putte JJ, Dijken WA, Kamp JS, Blansjaar BA, Kramer HJ, et al. Treatment strategy in depression. II. MAO inhibitors in depression resistant to cyclic antidepressants: two controlled crossover studies with tranylcypromine versus L-5-hydroxytryptophan and nomifensine. Acta Psychiatr Scand. Dec. 1988;78(6):676-83. [pmid: 3146891].
897 Nolen WA, van de Putte JJ, Dijken WA, Kamp JS, Blansjaar BA, Kramer HJ, et al. Treatment strategy in depression. I. Non-tricyclic and selective reuptake inhibitors in resistant depression: a double-blind partial crossover study on the effects of oxaprotiline and fluvoxamine. Acta Psychiatr Scand. Dec. 1988;78(6):668-75. [pmid: 3146890].
898 Nurnberg HG, Seidman SN, Gelenberg AJ, Fava M, Rosen R, Shabsigh R. Depression, antidepressant therapies, and erectile dysfunction: clinical trials of sildenafil citrate (Viagra) in treated and untreated patients with depression. Urology. Sep. 2002;60(2 Suppl 2):58-66. [pmid: 12414334].
899 Nutt DJ, Baldwin DS, Clayton AH, Elgie R, Lecrubier Y, Montejo AL, et al. Consensus statement and research needs: the role of dopamine and norepinephrine in depression and antidepressant treatment. J Clin Psychiatry. 6. 2006;67:46-9. [pmid: 16848678].
900 Obergriesser T, Ende G, Braus DF, Henn FA. Long-term follow-up of magnetic resonance-detectable choline signal changes in the hippocampus of patients treated with electroconvulsive therapy. J Clin Psychiatry. Jul. 2003;64(7):775-80. [pmid: 12934977].
901 O'Brien SM, Scully P, Fitzgerald P, Scott LV, Dinan TG. Plasma cytokine profiles in depressed patients who fail to respond to selective serotonin reuptake inhibitor therapy. J Psychiatr Res. Apr-Jun. 2007;41(3-4):326-31. [pmid: 16870211].
902 O'Connor DW, Gardner B, Eppingstall B, Tofler D. Cognition in elderly patients receiving unilateral and bilateral electroconvulsive therapy: a prospective, naturalistic comparison. J Affect Disord. Aug. 2010;124(3):235-40. [pmid: 20053457].
903 O'Connor KP, Colter N, Shaw JC. Cognitive style, cortical function, and electroconvulsive therapy. J Nerv Ment Dis. Dec. 1984;172(12):711-7. [pmid: 6502149].
904 O'Connor M, Brenninkmeyer C, Morgan A, Bloomingdale K, Thall M, Vasile R, et al. Relative effects of repetitive transcranial magnetic stimulation and electroconvulsive therapy on mood and memory: a neurocognitive risk-benefit analysis. Cogn Behav Neurol. Jun. 2003;16(2):118-27. [pmid: 12799598].
905 Ogawa A, Ukai S, Shinosaki K, Yamamoto M, Kawaguchi S, Ishii R, et al. Slow repetitive transcranial magnetic stimulation increases somatosensory high-frequency oscillations in humans. Neurosci Lett. Apr. 1. 2004;358(3):193-6. [pmid: 15039114].
906 Ogawa K, Uema T, Motohashi N, Nishikawa M, Takano H, Hiroki M, et al. Neural mechanism of propofol anesthesia in severe depression: a positron emission tomographic study. Anesthesiology. May. 2003;98(5):1101-11. [pmid: 12717131].
907 O'Keane V, Dinan TG, Scott L, Corcoran C. Changes in hypothalamic-pituitary-adrenal axis measures after vagus nerve stimulation therapy in chronic depression. Biol Psychiatry. Dec. 15. 2005;58(12):963-8. [pmid: 16005439].
908 O'Keane V, McLoughlin D, Dinan TG. D-fenfluramine-induced prolactin and cortisol release in major depression: response to treatment. J Affect Disord. Nov. 1992;26(3):143-50. [pmid: 1460163].
909 O'Leary DA, Lee AS. Seven year prognosis in depression. Mortality and readmission risk in the Nottingham ECT cohort. Br J Psychiatry. Oct. 1996;169(4):423-9. [pmid: 8894191].
910 Olver JS, Cryan JF, Burrows GD, Norman TR. Pindolol augmentation of antidepressants: a review and rationale. Aust N Z J Psychiatry. Feb. 2000;34(1):71-9. [pmid: 11185947].
911 Onder E, Tural U. Faster response in depressive patients treated with fluoxetine alone than in combination with buspirone. J Affect Disord. Sep. 2003;76(1-3):223-7. [pmid: 12943952].
912 Onishi Y, Kikuchi S, Watanabe E, Kato S. Alterations in prefrontal cortical activity in the course of treatment for late-life depression as assessed on near-infrared spectroscopy. Psychiatry Clin Neurosci. Apr. 2008;62(2):177-84. [pmid: 18412840].
913 Ontiveros A, Fontaine R, Elie R. Refractory depression: the addition of lithium to fluoxetine or desipramine. Acta Psychiatr Scand. Mar. 1991;83(3):188-92. [pmid: 1903237].
914 Oquendo MA, Malone KM, Mann JJ. Suicide: risk factors and prevention in refractory major depression. Depress Anxiety. 1997;5(4):202-11. [pmid: 9338112].
915 O'Reardon JP. Pharmacologic and therapeutic strategies in treatment-resistant depression. Introduction and clinical presentations. CNS Spectr. Mar. 2009;14(3 Suppl 4):4-6. [pmid: 19407713].
916 O'Reardon JP, Chopra MP, Bergan A, Gallop R, DeRubeis RJ, Crits-Christoph P. Response to tryptophan depletion in major depression treated with either cognitive therapy or selective serotonin reuptake inhibitor antidepressants. Biol Psychiatry. May. 1. 2004;55(9):957-9. [pmid: 15110741].
917 O'Reardon JP, Cristancho P, Pilania P, Bapatla KB, Chuai S, Peshek AD. Patients with a major depressive episode responding to treatment with repetitive transcranial magnetic stimulation (rTMS) are resistant to the effects of rapid tryptophan depletion. Depress Anxiety. 2007;24(8):537-44. [pmid: 17131353].
918 O'Reardon JP, Solvason HB, Janicak PG, Sampson S, Isenberg KE, Nahas Z, et al. Efficacy and safety of transcranial magnetic stimulation in the acute treatment of major depression: a multisite randomized controlled trial. Biol Psychiatry. 2007:1208-16.
919 Orengo CA, Fullerton L, Kunik ME. Safety and efficacy of testosterone gel 1% augmentation in depressed men with partial response to antidepressant therapy. J Geriatr Psychiatry Neurol. Mar. 2005;18(1):20-4. [pmid: 15681624].
920 Oyefeso A, Valmana A, Clancy C, Ghodse H, Williams H. Fatal antidepressant overdose among drug abusers and non-drug abusers. Acta Psychiatr Scand. Oct. 2000;102(4):295-9. [pmid: 11089730].
921 Padberg F, Schule C, Zwanzger P, Baghai T, Ella R, Mikhaiel P, et al. Relation between responses to repetitive transcranial magnetic stimulation and partial sleep deprivation in major depression. J Psychiatr Res. May-Jun. 2002;36(3):131-5. [pmid: 11886690].
922 Padberg F, Zwanzger P, Keck ME, Kathmann N, Mikhaiel P, Ella R, et al. Repetitive transcranial magnetic stimulation (rTMS) in major depression: relation between efficacy and stimulation intensity. Neuropsychopharmacology. Oct. 2002;27(4):638-45. [pmid: 12377400].
923 Padberg F, Zwanzger P, Thoma H, Kathmann N, Haag C, Greenberg BD, et al. Repetitive transcranial magnetic stimulation (rTMS) in pharmacotherapy-refractory major depression: comparative study of fast, slow and sham rTMS. Psychiatry Res. 1999:163-71.
924 Pae CU, Mandelli L, Han C, Ham BJ, Masand PS, Patkar AA, et al. Thyroid hormones affect recovery from depression during antidepressant treatment. Psychiatry Clin Neurosci. Jun. 2009;63(3):305-13. [pmid: 19566761].
925 Pae CU, Marks DM, Masand PS, Peindl K, Hooper-Wood C, Han C, et al. Methylphenidate extended release (OROS MPH) for the treatment of antidepressant-related sexual dysfunction in patients with treatment-resistant depression: results from a 4-week, double-blind, placebo-controlled trial. Clin Neuropharmacol. Mar-Apr. 2009;32(2):85-8. [pmid: 19512961].
926 Pae CU, Patkar AA, Jun TY, Lee C, Masand PS, Paik IH. Aripiprazole augmentation for treatment of patients with inadequate antidepressants response. Depress Anxiety. 2007;24(7):522-6. [pmid: 17111388].
927 Pagnin D, de Queiroz V, Pini S, Cassano GB. Efficacy of ECT in depression: a meta-analytic review. J Ect. Mar. 2004;20(1):13-20. [pmid: 15087991].
928 Pallanti S, Bernardi S, Di Rollo A, Antonini S, Quercioli L. Unilateral low frequency versus sequential bilateral repetitive transcranial magnetic stimulation: is simpler better for treatment of resistant depression?. Neuroscience. 2010/02/11. 2010:323-8.
929 Pande AC, Grunhaus LJ, Aisen AM, Haskett RF. A preliminary magnetic resonance imaging study of ECT-treated depressed patients. Biol Psychiatry. Jan. 1. 1990;27(1):102-4. [pmid: 2297546].
930 Pangalos MN, Malizia AL, Francis PT, Lowe SL, Bertolucci PH, Procter AW, et al. Effect of psychotropic drugs on excitatory amino acids in patients undergoing psychosurgery for depression. Br J Psychiatry. May. 1992;160:638-42. [pmid: 1350494].
931 Papakostas GI. Augmentation of standard antidepressants with atypical antipsychotic agents for treatment-resistant major depressive disorder. Essent Psychopharmacol. 2005;6(4):209-20. [pmid: 16041917].
932 Papakostas GI. Managing partial response or nonresponse: switching, augmentation, and combination strategies for major depressive disorder. J Clin Psychiatry. 6. 2009;70:16-25. [pmid: 19922740].
933 Papakostas GI. Pharmacologic and therapeutic strategies in treatment-resistant depression. Switching antidepressants vs. conventional augmentation strategies. CNS Spectr. Mar. 2009;14(3 Suppl 4):11-4. [pmid: 19407715].
934 Papakostas GI, Fava M, Thase ME. Treatment of SSRI-resistant depression: a meta-analysis comparing within- versus across-class switches. Biol Psychiatry. Apr. 1. 2008;63(7):699-704. [pmid: 17919460].
935 Papakostas GI, Petersen T, Denninger J, Sonawalla SB, Mahal Y, Alpert JE, et al. Somatic symptoms in treatment-resistant depression. Psychiatry Res. May. 1. 2003;118(1):39-45. [pmid: 12759160].
936 Papakostas GI, Petersen T, Iosifescu DV, Roffi PA, Alpert JE, Rosenbaum JF, et al. Axis III disorders in treatment-resistant major depressive disorder. Psychiatry Res. May. 30. 2003;118(2):183-8. [pmid: 12798983].
937 Papakostas GI, Petersen T, Mischoulon D, Ryan JL, Nierenberg AA, Bottiglieri T, et al. Serum folate, vitamin B12, and homocysteine in major depressive disorder, Part 1: predictors of clinical response in fluoxetine-resistant depression. J Clin Psychiatry. Aug. 2004;65(8):1090-5. [pmid: 15323594].
938 Papakostas GI, Petersen T, Worthington JJ, Roffi PA, Alpert JE, Fava M, et al. A pilot, open study of sertraline in outpatients with treatment-resistant depression (TRD) or with a history of TRD who responded but later relapsed. Int Clin Psychopharmacol. Sep. 2003;18(5):293-6. [pmid: 12920390].
939 Papakostas GI, Petersen TJ, Green C, Iosifescu DV, Yeung AS, Nierenberg AA, et al. A description of next-step switching versus augmentation practices for outpatients with treatment-resistant major depressive disorder enrolled in an academic specialty clinic. Ann Clin Psychiatry. Jul-Sep. 2005;17(3):161-5. [pmid: 16433058].
940 Papakostas GI, Shelton RC, Smith J, Fava M. Augmentation of antidepressants with atypical antipsychotic medications for treatment-resistant major depressive disorder: a meta-analysis. J Clin Psychiatry. Jun. 2007;68(6):826-31. [pmid: 17592905].
941 Papakostas GI, Worthington JJ 3rd, Iosifescu DV, Kinrys G, Burns AM, Fisher LB, et al. The combination of duloxetine and bupropion for treatment-resistant major depressive disorder. Depress Anxiety. 2006;23(3):178-81. [pmid: 16528701].
942 Papakostas Y, Markianos M, Pehlivanidis A, Papadimitriou GN, Zervas IM, Daras M, et al. Effects of thyrotropin-releasing hormone administration on the electroconvulsive therapy induced prolactin responses and seizure time. Biol Psychiatry. Mar. 15. 1996;39(6):444-7. [pmid: 8679790].
943 Papakostas YG, Markianos M, Zervas IM, Theodoropoulou M, Vaidakis N, Daras M. Administration of citalopram before ECT: seizure duration and hormone responses. J Ect. Dec. 2000;16(4):356-60. [pmid: 11314873].
944 Papavasiliou PS, Miller ST, Palat G, Pleban P, Mostek W. Selective disturbances of serum mineral profiles by electroconvulsive therapy. J Nerv Ment Dis. Jul. 1985;173(7):401-5. [pmid: 4009156].
945 Pardo JV, Sheikh SA, Kuskowski MA, Surerus-Johnson C, Hagen MC, Lee JT, et al. Weight loss during chronic, cervical vagus nerve stimulation in depressed patients with obesity: an observation. Int J Obes (Lond). Nov. 2007;31(11):1756-9. [pmid: 17563762].
946 Pardo JV, Sheikh SA, Schwindt GC, Lee JT, Kuskowski MA, Surerus C, et al. Chronic vagus nerve stimulation for treatment-resistant depression decreases resting ventromedial prefrontal glucose metabolism. Neuroimage. Aug. 15. 2008;42(2):879-89. [pmid: 18595737].
947 Parker G, Hadzi-Pavlovic D, Hickie I, Mitchell P, Wilhelm K, Brodaty H, et al. Psychotic depression: a review and clinical experience. Aust N Z J Psychiatry. Jun. 1991;25(2):169-80. [pmid: 1678937].
948 Parker G, Roy K, Wilhelm K, Mitchell P. Assessing the comparative effectiveness of antidepressant therapies: a prospective clinical practice study. J Clin Psychiatry. Feb. 2001;62(2):117-25. [pmid: 11247097].
949 Pary R, Tobias CR, Lippmann S. Pharmacologic treatment strategies for the depressed, poorly responsive patient. South Med J. Nov. 1992;85(11):1122-6. 30. [pmid: 1439951].
950 Pascual-Leone A, Rubio B, Pallardo F, Catala MD. Rapid-rate transcranial magnetic stimulation of left dorsolateral prefrontal cortex in drug-resistant depression. Lancet. Jul. 27. 1996;348(9022):233-7. [pmid: 8684201].
951 Passard A, Attal N, Benadhira R, Brasseur L, Saba G, Sichere P, et al. Effects of unilateral repetitive transcranial magnetic stimulation of the motor cortex on chronic widespread pain in fibromyalgia. Brain. Oct. 2007;130(Pt 10):2661-70. [pmid: 17872930].
952 Patankar TF, Baldwin R, Mitra D, Jeffries S, Sutcliffe C, Burns A, et al. Virchow-Robin space dilatation may predict resistance to antidepressant monotherapy in elderly patients with depression. J Affect Disord. Jan. 2007;97(1-3):265-70. [pmid: 16919335].
953 Patkar AA, Pae CU, Masand PS. Transdermal selegiline: the new generation of monoamine oxidase inhibitors. CNS Spectr. May. 2006;11(5):363-75. [pmid: 16641841].
954 Patkar AA, Pae CU, Zarzar M. Transdermal selegiline. Drugs Today (Barc). Jun. 2007;43(6):361-77. [pmid: 17612708].
955 Patten SB, Lupin DA, Boucher SA, Lamarre CJ. Pharmacologic management of refractory depression. Cmaj. Feb. 15. 1992;146(4):483-7. [pmid: 1737312].
956 Payne ME, Hybels CF, Bales CW, Steffens DC. Vascular nutritional correlates of late-life depression. Am J Geriatr Psychiatry. Sep. 2006;14(9):787-95. [pmid: 16943175].
957 Penttila J, Paillere-Martinot ML, Martinot JL, Ringuenet D, Wessa M, Houenou J, et al. Cortical folding in patients with bipolar disorder or unipolar depression. J Psychiatry Neurosci. Mar. 2009;34(2):127-35. [pmid: 19270763].
958 Perera TD, Luber B, Nobler MS, Prudic J, Anderson C, Sackeim HA. Seizure expression during electroconvulsive therapy: relationships with clinical outcome and cognitive side effects. Neuropsychopharmacology. Apr. 2004;29(4):813-25. [pmid: 14735129].
959 Peretti CS, Danion JM, Grange D, Mobarek N. Bilateral ECT and autobiographical memory of subjective experiences related to melancholia: a pilot study. J Affect Disord. Nov. 4. 1996;41(1):9-15. [pmid: 8938200].
960 Perez V, Soler J, Puigdemont D, Alvarez E, Artigas F. A double-blind, randomized, placebo-controlled trial of pindolol augmentation in depressive patients resistant to serotonin reuptake inhibitors. Grup de Recerca en Trastorns Afectius. Arch Gen Psychiatry. Apr. 1999;56(4):375-9. [pmid: 10197835].
961 Perlis RH, Alpert J, Nierenberg AA, Mischoulon D, Yeung A, Rosenbaum JF, et al. Clinical and sociodemographic predictors of response to augmentation, or dose increase among depressed outpatients resistant to fluoxetine 20 mg/day. Acta Psychiatr Scand. Dec. 2003;108(6):432-8. [pmid: 14616224].
962 Perlis RH, Iosifescu DV, Alpert J, Nierenberg AA, Rosenbaum JF, Fava M. Effect of medical comorbidity on response to fluoxetine augmentation or dose increase in outpatients with treatment-resistant depression. Psychosomatics. May-Jun. 2004;45(3):224-9. [pmid: 15123848].
963 Perry EB, Berman RM, Sanacora G, Anand A, Lynch-Colonese K, Charney DS. Pindolol augmentation in depressed patients resistant to selective serotonin reuptake inhibitors: a double-blind, randomized, controlled trial. J Clin Psychiatry. Feb. 2004;65(2):238-43. [pmid: 15003079].
964 Perry PJ, Morgan DE, Smith RE, Tsuang MT. Treatment of unipolar depression accompanied by delusions. ECT versus tricyclic antidepressant--antipsychotic combinations. J Affect Disord. Sep. 1982;4(3):195-200. [pmid: 6127358].
965 Perry SW 3rd. HIV-related depression. Res Publ Assoc Res Nerv Ment Dis. 1994;72:223-38. [pmid: 8115715].
966 Perugi G, Akiskal HS, Micheli C, Toni C, Madaro D. Clinical characterization of depressive mixed state in bipolar-I patients: Pisa-San Diego collaboration. J Affect Disord. Dec. 2001;67(1-3):105-14. [pmid: 11869757].
967 Peschina W, Conca A, Konig P, Fritzsche H, Beraus W. Low frequency rTMS as an addon antidepressive strategy: heterogeneous impact on 99mTc-HMPAO and 18 F-FDG uptake as measured simultaneously with the double isotope SPECT technique. Pilot study. Nucl Med Commun. Aug. 2001;22(8):867-73. [pmid: 11473205].
968 Peters EJ, Slager SL, Kraft JB, Jenkins GD, Reinalda MS, McGrath PJ, et al. Pharmacokinetic genes do not influence response or tolerance to citalopram in the STAR*D sample. PLoS One. 2008;3(4):e1872. [pmid: 18382661].
969 Peters EJ, Slager SL, McGrath PJ, Knowles JA, Hamilton SP. Investigation of serotonin-related genes in antidepressant response. Mol Psychiatry. Sep. 2004;9(9):879-89. [pmid: 15052272].
970 Petersen T, Papakostas GI, Posternak MA, Kant A, Guyker WM, Iosifescu DV, et al. Empirical testing of two models for staging antidepressant treatment resistance. J Clin Psychopharmacol. Aug. 2005;25(4):336-41. [pmid: 16012276].
971 Petrides G, Fink M, Husain MM, Knapp RG, Rush AJ, Mueller M, et al. ECT remission rates in psychotic versus nonpsychotic depressed patients: a report from CORE. J Ect. Dec. 2001;17(4):244-53. [pmid: 11731725].
972 Pettinati HM, Nilsen S. Missed and brief seizures during ECT: differential response between unilateral and bilateral electrode placement. Biol Psychiatry. May. 1985;20(5):506-14. [pmid: 3986258].
973 Pettinati HM, Rosenberg J. Memory self-ratings before and after electroconvulsive therapy: depression-versus ECT induced. Biol Psychiatry. Apr. 1984;19(4):539-48. [pmid: 6733173].
974 Phanjoo A. The elderly depressed and treatment with fluvoxamine. Int Clin Psychopharmacol. Dec. 3. 1991;6:33-7. discussion 7-9. [pmid: 1806633].
975 Philip NS, Carpenter LL, Tyrka AR, Price LH. Augmentation of antidepressants with atypical antipsychotics: a review of the current literature. J Psychiatr Pract. Jan. 2008;14(1):34-44. [pmid: 18212601].
976 Philip NS, Carpenter LL, Tyrka AR, Price LH. Pharmacologic approaches to treatment resistant depression: a re-examination for the modern era. Expert Opin Pharmacother. Apr. 2010;11(5):709-22. [pmid: 20151847].
977 Phillips KA. Body dysmorphic disorder: diagnostic controversies and treatment challenges. Bull Menninger Clin. Winter. 2000;64(1):18-35. [pmid: 10695157].
978 Phillips KA, Nierenberg AA. The assessment and treatment of refractory depression. J Clin Psychiatry. Feb. Suppl. 1994;55:20-6. [pmid: 8077165].
979 Pinar M, Gulsun M, Tasci I, Erdil A, Bolu E, Acikel C, et al. Maprotiline induced weight gain in depressive disorder: changes in circulating ghrelin and adiponectin levels and insulin sensitivity. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 1. 2008;32(1):135-9. [pmid: 17825464].
980 Pisvejc J, Hyrman V, Sikora J, Berankova A, Kobeda B, Auerova M, et al. A comparison of brief and ultrabrief pulse stimuli in unilateral ECT. J Ect. Jun. 1998;14(2):68-75. [pmid: 9641801].
981 Pluijms EM, Birkenhager TK, Huijbrechts IP, Moleman P. Influence of resistance to antidepressant pharmacotherapy on short-term response to electroconvulsive therapy. J Affect Disord. May. 2002;69(1-3):93-9. [pmid: 12103456].
982 Podawiltz A, Culpepper L. Treatment-resistant depression in Hispanic patients. J Clin Psychiatry. Jun. 2010;71(6):e12. [pmid: 20573322].
983 Pogarell O, Koch W, Popperl G, Tatsch K, Jakob F, Mulert C, et al. Acute prefrontal rTMS increases striatal dopamine to a similar degree as D-amphetamine. Psychiatry Res. Dec. 15. 2007;156(3):251-5. [pmid: 17993266].
984 Poirier MF, Boyer P. Venlafaxine and paroxetine in treatment-resistant depression. Double-blind, randomised comparison. Br J Psychiatry. 1999:12-6.
985 Pope HG Jr, Cohane GH, Kanayama G, Siegel AJ, Hudson JI. Testosterone gel supplementation for men with refractory depression: a randomized, placebo-controlled trial. Am J Psychiatry. Jan. 2003;160(1):105-11. [pmid: 12505808].
986 Posternak MA, Solomon DA, Leon AC, Mueller TI, Shea MT, Endicott J, et al. The naturalistic course of unipolar major depression in the absence of somatic therapy. J Nerv Ment Dis. May. 2006;194(5):324-9. [pmid: 16699380].
987 Posternak MA, Zimmerman M. Short-term spontaneous improvement rates in depressed outpatients. J Nerv Ment Dis. Dec. 2000;188(12):799-804. [pmid: 11191579].
988 Poulet E, Brunelin J, Boeuve C, Lerond J, D'Amato T, Dalery J, et al. Repetitive transcranial magnetic stimulation does not potentiate antidepressant treatment. Eur Psychiatry. Sep. 2004;19(6):382-3. [pmid: 15363481].
989 Powers RH, Kniesner TJ, Croghan TW. Psychotherapy and pharmacotherapy in depression. J Ment Health Policy Econ. Dec. 2002;5(4):153-61. [pmid: 14578549].
990 Preskorn SH. Treatment options for the patient who does not respond well to initial antidepressant therapy. J Psychiatr Pract. May. 2009;15(3):202-10. [pmid: 19461393].
991 Preskorn SH. Outliers on the dose-response curve: how to minimize this problem using therapeutic drug monitoring, an underutilized tool in psychiatry. J Psychiatr Pract. May. 2010;16(3):177-82. [pmid: 20485106].
992 Preskorn SH, Baker B, Kolluri S, Menniti FS, Krams M, Landen JW. An innovative design to establish proof of concept of the antidepressant effects of the NR2B subunit selective N-methyl-D-aspartate antagonist, CP-101,606, in patients with treatment-refractory major depressive disorder. J Clin Psychopharmacol. Dec. 2008;28(6):631-7. [pmid: 19011431].
993 Price GW, Lee JW, Garvey CA, Gibson N. The use of background EEG activity to determine stimulus timing as a means of improving rTMS efficacy in the treatment of depression: a controlled comparison with standard techniques. Brain Stimul. Jul. 2010;3(3):140-52. [pmid: 20633443].
994 Price LH, Charney DS, Delgado PL, Heninger GR. Fenfluramine augmentation in tricyclic-refractory depression. J Clin Psychopharmacol. Oct. 1990;10(5):312-7. [pmid: 2258448].
995 Price LH, Charney DS, Heninger GR. Efficacy of lithium-tranylcypromine treatment in refractory depression. Am J Psychiatry. May. 1985;142(5):619-23. [pmid: 3920923].
996 Price LH, Charney DS, Heninger GR. Variability of response to lithium augmentation in refractory depression. Am J Psychiatry. Nov. 1986;143(11):1387-92. [pmid: 3096155].
997 Price LH, Charney DS, Heninger GR. Reserpine augmentation of desipramine in refractory depression: clinical and neurobiological effects. Psychopharmacology (Berl). 1987;92(4):431-7. [pmid: 2442788].
998 Pridmore S. Substitution of rapid transcranial magnetic stimulation treatments for electroconvulsive therapy treatments in a course of electroconvulsive therapy. Depress Anxiety. 2000;12(3):118-23. [pmid: 11126185].
999 Pridmore S, Turnier-Shea Y. Medication options in the treatment of treatment-resistant depression. Aust N Z J Psychiatry. Apr. 2004;38(4):219-25. [pmid: 15038800].
1000 Priest R. Therapy-resistant depression. Workshop report. Int Clin Psychopharmacol. Jan. 1993;7(3-4):201-2. [pmid: 8468443].
1001 Prohovnik I, Sackeim HA, Decina P, Malitz S. Acute reductions of regional cerebral blood flow following electroconvulsive therapy. Interactions with modality and time. Ann N Y Acad Sci. 1986;462:249-62. [pmid: 3458407].
1002 Prudic J, Fitzsimons L, Nobler MS, Sackeim HA. Naloxone in the prevention of the adverse cognitive effects of ECT: a within-subject, placebo controlled study. Neuropsychopharmacology. Aug. 1999;21(2):285-93. [pmid: 10432476].
1003 Prudic J, Haskett RF, Mulsant B, Malone KM, Pettinati HM, Stephens S, et al. Resistance to antidepressant medications and short-term clinical response to ECT. Am J Psychiatry. Aug. 1996;153(8):985-92. [pmid: 8678194].
1004 Prudic J, Olfson M, Marcus SC, Fuller RB, Sackeim HA. Effectiveness of electroconvulsive therapy in community settings. Biol Psychiatry. Feb. 1. 2004;55(3):301-12. [pmid: 14744473].
1005 Prudic J, Sackeim HA, Decina P, Hopkins N, Ross FR, Malitz S. Acute effects of ECT on cardiovascular functioning: relations to patient and treatment variables. Acta Psychiatr Scand. Apr. 1987;75(4):344-51. [pmid: 3591419].
1006 Prudic J, Sackeim HA, Devanand DP, Krueger RB, Settembrino JM. Acute cognitive effects of subconvulsive electrical stimulation. Convuls Ther. Mar. 1994;10(1):4-24. [pmid: 8055291].
1007 Quilty LC, De Fruyt F, Rolland JP, Kennedy SH, Rouillon PF, Bagby RM. Dimensional personality traits and treatment outcome in patients with major depressive disorder. J Affect Disord. Jun. 2008;108(3):241-50. [pmid: 18067975].
1008 Quitkin FM. The importance of dosage in prescribing antidepressants. Br J Psychiatry. Dec. 1985;147:593-7. [pmid: 3913485].
1009 Quitkin FM, McGrath P, Liebowitz MR, Stewart J, Howard A. Monoamine oxidase inhibitors in bipolar endogenous depressives. J Clin Psychopharmacol. Mar. 1981;1(2):70-4. [pmid: 7028797].
1010 Rabins PV, Pearlson GD, Aylward E, Kumar AJ, Dowell K. Cortical magnetic resonance imaging changes in elderly inpatients with major depression. Am J Psychiatry. May. 1991;148(5):617-20. [pmid: 2018163].
1011 Rado J, Janicak PG. Vagus nerve stimulation for severe depression. J Psychosoc Nurs Ment Health Serv. Jul. 2007;45(7):43-51. [pmid: 17679315].
1012 Railton R, Fisher J, Sinclair A, Shrigmankar JM. Comparison of electrical measurements on constant voltage and constant current ECT machines. Br J Psychiatry. Aug. 1987;151:244-7. [pmid: 3690115].
1013 Ramasubbu R. Insulin resistance: a metabolic link between depressive disorder and atherosclerotic vascular diseases. Med Hypotheses. Nov. 2002;59(5):537-51. [pmid: 12376076].
1014 Rami L, Goti J, Ferrer J, Marcos T, Salamero M, Bernardo M. Cognitive functions after only one ECT session: a controlled study. Psychiatry Res. Apr. 15. 2008;158(3):389-94. [pmid: 18279973].
1015 Ranjkesh F, Barekatain M, Akuchakian S. Bifrontal versus right unilateral and bitemporal electroconvulsive therapy in major depressive disorder. J Ect. Dec. 2005;21(4):207-10. [pmid: 16301878].
1016 Rasgon NL, Kenna HA, Williams KE, Powers B, Wroolie T, Schatzberg AF. Rosiglitazone add-on in treatment of depressed patients with insulin resistance: a pilot study. ScientificWorldJournal. 2010;10:321-8. [pmid: 20191245].
1017 Rasmussen KG, Black JL. Serotonin transporter gene status and electroconvulsive therapy outcomes: a retrospective analysis of 83 patients. J Clin Psychiatry. Jan. 2009;70(1):92-4. [pmid: 19192461].
1018 Rasmussen KG, Knapp RG, Biggs MM, Smith GE, Rummans TA, Petrides G, et al. Data management and design issues in an unmasked randomized trial of electroconvulsive therapy for relapse prevention of severe depression: the consortium for research in electroconvulsive therapy trial. J Ect. Dec. 2007;23(4):244-50. [pmid: 18090697].
1019 Rasmussen KG, Mueller M, Rummans TA, Husain MM, Petrides G, Knapp RG, et al. Is baseline medication resistance associated with potential for relapse after successful remission of a depressive episode with ECT? Data from the Consortium for Research on Electroconvulsive Therapy (CORE). J Clin Psychiatry. Feb. 2009;70(2):232-7. [pmid: 19192459].
1020 Rasmussen KG, Snyder KA, Knapp RG, Mueller M, Yim E, Husain MM, et al. Relationship between somatization and remission with ECT. Psychiatry Res. Dec. 30. 2004;129(3):293-5. [pmid: 15661324].
1021 Rasmussen LB, Mikkelsen K, Haugen M, Pripp AH, Forre OT. Treatment of fibromyalgia at the Maharishi Ayurveda Health Centre in Norway. A six-month follow-up study. Clin Exp Rheumatol. Sep-Oct. 2009;27(5 Suppl 56):S46-50. [pmid: 20074439].
1022 Rasmussen NA, Schroder P, Olsen LR, Brodsgaard M, Unden M, Bech P. Modafinil augmentation in depressed patients with partial response to antidepressants: a pilot study on self-reported symptoms covered by the Major Depression Inventory (MDI) and the Symptom Checklist (SCL-92). Nord J Psychiatry. 2005;59(3):173-8. [pmid: 16208839].
1023 Rasmussen-Torvik LJ, McAlpine DD. Genetic screening for SSRI drug response among those with major depression: great promise and unseen perils. Depress Anxiety. 2007;24(5):350-7. [pmid: 17096399].
1024 Ravindran AV. If a patient does not respond to a full dose of fluvoxamine for at least 12 weeks, what alternatives should be considered?. J Psychiatry Neurosci. Mar. 1998;23(2):136.
1025 Recart A, Rawal S, White PF, Byerly S, Thornton L. The effect of remifentanil on seizure duration and acute hemodynamic responses to electroconvulsive therapy. Anesth Analg. Apr. 2003;96(4):1047-50. table of contents. [pmid: 12651657].
1026 Regenold WT, Hisley KC, Obuchowski A, Lefkowitz DM, Marano C, Hauser P. Relationship of white matter hyperintensities to cerebrospinal fluid glucose polyol pathway metabolites-a pilot study in treatment-resistant affective disorder patients. J Affect Disord. Apr. 2005;85(3):341-50. [pmid: 15780705].
1027 Regestein QR, Monk TH. Delayed sleep phase syndrome: a review of its clinical aspects. Am J Psychiatry. Apr. 1995;152(4):602-8. [pmid: 7694911].
1028 Reimherr F, Amsterdam J, Dunner D, Adler L, Zhang S, Williams D, et al. Genetic polymorphisms in the treatment of depression: speculations from an augmentation study using atomoxetine. Psychiatry Res. Jan. 30. 2010;175(1-2):67-73. [pmid: 19969374].
1029 Remick RA. Treatment resistant depression. Psychiatr J Univ Ott. Jun. 1989;14(2):394-6. [pmid: 2668994].
1030 Repo-Tiihonen E, Eloranta A, Hallikainen T, Tiihonen J. Effects of venlafaxine treatment on clozapine plasma levels in schizophrenic patients. Neuropsychobiology. 2005;51(4):173-6. [pmid: 15870506].
1031 Reus VI. Management of treatment-resistant unipolar and chronically depressed patients. Psychiatr Clin North Am. Jun. 1996;19(2):201-13. [pmid: 8827186].
1032 Rich CL, Spiker DG, Jewell SW, Neil JF, Phillipson M. ECT response in psychotic versus nonpsychotic unipolar depressives. J Clin Psychiatry. Mar. 1986;47(3):123-5. [pmid: 3949720].
1033 Richelson E. Treatment of acute depression. Psychiatr Clin North Am. Sep. 1993;16(3):461-78. [pmid: 8415232].
1034 Riddle WJ, Scott AI, Bennie J, Carroll S, Fink G. Current intensity and oxytocin release after electroconvulsive therapy. Biol Psychiatry. Jun. 1-15. 1993;33(11-12):839-41. [pmid: 8373922].
1035 Robin A, De Tissera S. A double-blind controlled comparison of the therapeutic effects of low and high energy electroconvulsive therapies. Br J Psychiatry. Oct. 1982;141:357-66. [pmid: 6756529].
1036 Robinson RG, Tenev V, Jorge RE. Citalopram for continuation therapy after repetitive transcranial magnetic stimulation in vascular depression. Am J Geriatr Psychiatry. Aug. 2009;17(8):682-7. [pmid: 19625785].
1037 Rocca P, Marchiaro L, Rasetti R, Rivoira E, Bogetto F. A comparison of paroxetine versus paroxetine plus amisulpride in the treatment of dysthymic disorder: efficacy and psychosocial outcomes. Psychiatry Res. Oct. 10. 2002;112(2):145-52. [pmid: 12429360].
1038 Rodger CR, Scott AI, Whalley LJ. Is there a delay in the onset of the antidepressant effect of electroconvulsive therapy?. Br J Psychiatry. Jan. 1994;164(1):106-9. [pmid: 8137089].
1039 Roemer RA, Shagass C, Dubin W, Jaffe R, Katz R. Relationship between pretreatment electroencephalographic coherence measures and subsequent response to electroconvulsive therapy: a preliminary study. Neuropsychobiology. 1990;24(3):121-4. [pmid: 2135066].
1040 Rogoz Z, Dziedzicka-Wasylewska M, Daniel WA, Wojcikowski J, Dudek D, Wrobel A, et al. Effects of joint administration of imipramine and amantadine in patients with drug-resistant unipolar depression. Pol J Pharmacol. Nov-Dec. 2004;56(6):735-42. [pmid: 15662086].
1041 Rogoz Z, Skuza G, Daniel WA, Wojcikowski J, Dudek D, Wrobel A. Amantadine as an additive treatment in patients suffering from drug-resistant unipolar depression. Pharmacol Rep. Nov-Dec. 2007;59(6):778-84. [pmid: 18195470].
1042 Rogoz Z, Skuza G, Wojcikowski J, Daniel WA, Wrobel A, Dudek D, et al. Effect of metyrapone supplementation on imipramine therapy in patients with treatment-resistant unipolar depression. Pol J Pharmacol. Nov-Dec. 2004;56(6):849-55. [pmid: 15662100].
1043 Rohan KJ, Lindsey KT, Roecklein KA, Lacy TJ. Cognitive-behavioral therapy, light therapy, and their combination in treating seasonal affective disorder. J Affect Disord. Jun. 2004;80(2-3):273-83. [pmid: 15207942].
1044 Rohland BM. Self-report of improvement following hospitalization for electroconvulsive therapy: relationship to functional status and service use. Adm Policy Ment Health. Jan. 2001;28(3):193-203. [pmid: 11330015].
1045 Ros S, Aguera L, de la Gandara J, Rojo JE, de Pedro JM. Potentiation strategies for treatment-resistant depression. Acta Psychiatr Scand Suppl. 2005;(428):14-24. 36. [pmid: 16307616].
1046 Rosa MA, Gattaz WF, Pascual-Leone A, Fregni F, Rosa MO, Rumi DO, et al. Comparison of repetitive transcranial magnetic stimulation and electroconvulsive therapy in unipolar non-psychotic refractory depression: a randomized, single-blind study. Int J Neuropsychopharmacol. Dec. 2006;9(6):667-76. [pmid: 16923322].
1047 Rosa MA, Rosa MO, Marcolin MA, Fregni F. Cardiovascular effects of anesthesia in ECT: a randomized, double-blind comparison of etomidate, propofol, and thiopental. J Ect. Mar. 2007;23(1):6-8. [pmid: 17435563].
1048 Rosen I, Silfverskiold P. Quantification of EEG changes following electroconvulsive therapy in depression. Eur Arch Psychiatry Neurol Sci. 1987;236(4):209-13. [pmid: 3582429].
1049 Rosenbaum JF. Treatment-resistant panic disorder. J Clin Psychiatry. 2. 1997;58:61-4. discussion 5. [pmid: 9078997].
1050 Rosenquist PB, Dunn A, Rapp S, Gaba A, McCall WV. What predicts patients' expressed likelihood of choosing electroconvulsive therapy as a future treatment option?. J Ect. Mar. 2006;22(1):33-7. [pmid: 16633204].
1051 Rosenzweig-Lipson S, Beyer CE, Hughes ZA, Khawaja X, Rajarao SJ, Malberg JE, et al. Differentiating antidepressants of the future: efficacy and safety. Pharmacol Ther. Jan. 2007;113(1):134-53. [pmid: 17010443].
1052 Rossini D, Lucca A, Magri L, Malaguti A, Smeraldi E, Colombo C, et al. A symptom-specific analysis of the effect of high-frequency left or low-frequency right transcranial magnetic stimulation over the dorsolateral prefrontal cortex in major depression. Neuropsychobiology. 2010;62(2):91-7. [pmid: 20523080].
1053 Rossini D, Lucca A, Zanardi R, Magri L, Smeraldi E. Transcranial magnetic stimulation in treatment-resistant depressed patients: a double-blind, placebo-controlled trial. Psychiatry Res. Nov. 15. 2005;137(1-2):1-10. [pmid: 16225930].
1054 Rossini D, Magri L, Lucca A, Giordani S, Smeraldi E, Zanardi R. Does rTMS hasten the response to escitalopram, sertraline, or venlafaxine in patients with major depressive disorder? A double-blind, randomized, sham-controlled trial. J Clin Psychiatry. Dec. 2005;66(12):1569-75. [pmid: 16401159].
1055 Rouillon F, Gorwood P. The use of lithium to augment antidepressant medication. J Clin Psychiatry. 5. 1998;59:32-9. discussion 40-1. [pmid: 9635546].
1056 Rubin EH, Kinscherf DA, Figiel GS, Zorumski CF. The nature and time course of cognitive side effects during electroconvulsive therapy in the elderly. J Geriatr Psychiatry Neurol. Apr-Jun. 1993;6(2):78-83. [pmid: 8512634].
1057 Rubin RR, Gaussoin SA, Peyrot M, DiLillo V, Miller K, Wadden TA, et al. Cardiovascular disease risk factors, depression symptoms and antidepressant medicine use in the Look AHEAD (Action for Health in Diabetes) clinical trial of weight loss in diabetes. Diabetologia. Aug. 2010;53(8):1581-9. [pmid: 20422396].
1058 Rubio G, San L, Lopez-Munoz F, Alamo C. Reboxetine adjunct for partial or nonresponders to antidepressant treatment. J Affect Disord. Jul. 2004;81(1):67-72. [pmid: 15183602].
1059 Rudas S, Schmitz M, Pichler P, Baumgartner A. Treatment of refractory chronic depression and dysthymia with high-dose thyroxine. Biol Psychiatry. Jan. 15. 1999;45(2):229-33. [pmid: 9951571].
1060 Ruhe HG, Huyser J, Swinkels JA, Schene AH. Switching antidepressants after a first selective serotonin reuptake inhibitor in major depressive disorder: a systematic review. J Clin Psychiatry. Dec. 2006;67(12):1836-55. [pmid: 17194261].
1061 Rumi DO, Gattaz WF, Rigonatti SP, Rosa MA, Fregni F, Rosa MO, et al. Transcranial magnetic stimulation accelerates the antidepressant effect of amitriptyline in severe depression: a double-blind placebo-controlled study. Biol Psychiatry. Jan. 15. 2005;57(2):162-6. [pmid: 15652875].
1062 Rush AJ, Bose A, Heydorn WE. Naturalistic study of the early psychiatric use of citalopram in the United States. Depress Anxiety. 2002;16(3):121-7. [pmid: 12415537].
1063 Rush AJ, Sackeim HA, Marangell LB, George MS, Brannan SK, Davis SM, et al. Effects of 12 months of vagus nerve stimulation in treatment-resistant depression: a naturalistic study. Biol Psychiatry. Sep. 1. 2005;58(5):355-63. [pmid: 16139581].
1064 Rush AJ, Siefert SE. Clinical issues in considering vagus nerve stimulation for treatment-resistant depression. Exp Neurol. Sep. 2009;219(1):36-43. [pmid: 19397908].
1065 Rush AJ, Thase ME, Dube S. Research issues in the study of difficult-to-treat depression. Biol Psychiatry. Apr. 15. 2003;53(8):743-53. [pmid: 12706958].
1066 Russell JL. Relatively low doses of cisapride in the treatment of nausea in patients treated with venlafaxine for treatment-refractory depression. J Clin Psychopharmacol. Feb. 1996;16(1):35-7. [pmid: 8834416].
1067 Russell JM, Hawkins K, Ozminkowski RJ, Orsini L, Crown WH, Kennedy S, et al. The cost consequences of treatment-resistant depression. J Clin Psychiatry. Mar. 2004;65(3):341-7. [pmid: 15096073].
1068 Rutherford B, Sneed J, Miyazaki M, Eisenstadt R, Devanand D, Sackeim H, et al. An open trial of aripiprazole augmentation for SSRI non-remitters with late-life depression. Int J Geriatr Psychiatry. Oct. 2007;22(10):986-91. [pmid: 17340654].
1069 Rybakowski J, Matkowski K. Adding lithium to antidepressant therapy: factors related to therapeutic potentiation. Eur Neuropsychopharmacol. Jun. 1992;2(2):161-5. [pmid: 1633434].
1070 Rybakowski JK, Suwalska A, Chlopocka-Wozniak M. Potentiation of antidepressants with lithium or carbamazepine in treatment-resistant depression. Neuropsychobiology. Sep. 1999;40(3):134-9. [pmid: 10494048].
1071 Rybakowski JK, Suwalska A, Lojko D, Rymaszewska J, Kiejna A. Bipolar mood disorders among Polish psychiatric outpatients treated for major depression. J Affect Disord. Feb. 2005;84(2-3):141-7. [pmid: 15708411].
1072 Sachs GS. Treatment-resistant bipolar depression. Psychiatr Clin North Am. Jun. 1996;19(2):215-36. [pmid: 8827187].
1073 Sackeim H, Decina P, Prohovnik I, Malitz S. Seizure threshold in electroconvulsive therapy. Effects of sex, age, electrode placement, and number of treatments. Arch Gen Psychiatry. Apr. 1987;44(4):355-60. [pmid: 3566457].
1074 Sackeim HA. Continuation therapy following ECT: directions for future research. Psychopharmacol Bull. 1994;30(3):501-21. [pmid: 7878189].
1075 Sackeim HA. The definition and meaning of treatment-resistant depression. J Clin Psychiatry. 16. 2001;62:10-7. [pmid: 11480879].
1076 Sackeim HA, Brannan SK, Rush AJ, George MS, Marangell LB, Allen J. Durability of antidepressant response to vagus nerve stimulation (VNS). Int J Neuropsychopharmacol. Dec. 2007;10(6):817-26. [pmid: 17288644].
1077 Sackeim HA, Decina P, Kanzler M, Kerr B, Malitz S. Effects of electrode placement on the efficacy of titrated, low-dose ECT. Am J Psychiatry. Nov. 1987;144(11):1449-55. [pmid: 3314538].
1078 Sackeim HA, Decina P, Portnoy S, Neeley P, Malitz S. Studies of dosage, seizure threshold, and seizure duration in ECT. Biol Psychiatry. Mar. 1987;22(3):249-68. [pmid: 3814678].
1079 Sackeim HA, Dillingham EM, Prudic J, Cooper T, McCall WV, Rosenquist P, et al. Effect of concomitant pharmacotherapy on electroconvulsive therapy outcomes: short-term efficacy and adverse effects. Arch Gen Psychiatry. Jul. 2009;66(7):729-37. [pmid: 19581564].
1080 Sackeim HA, Freeman J, McElhiney M, Coleman E, Prudic J, Devanand DP. Effects of major depression on estimates of intelligence. J Clin Exp Neuropsychol. Mar. 1992;14(2):268-88. [pmid: 1572949].
1081 Sackeim HA, Haskett RF, Mulsant BH, Thase ME, Mann JJ, Pettinati HM, et al. Continuation pharmacotherapy in the prevention of relapse following electroconvulsive therapy: a randomized controlled trial. Jama. Mar. 14. 2001;285(10):1299-307. [pmid: 11255384].
1082 Sackeim HA, Keilp JG, Rush AJ, George MS, Marangell LB, Dormer JS, et al. The effects of vagus nerve stimulation on cognitive performance in patients with treatment-resistant depression. Neuropsychiatry Neuropsychol Behav Neurol. Jan. 2001;14(1):53-62. [pmid: 11234909].
1083 Sackeim HA, Luber B, Katzman GP, Moeller JR, Prudic J, Devanand DP, et al. The effects of electroconvulsive therapy on quantitative electroencephalograms. Relationship to clinical outcome. Arch Gen Psychiatry. Sep. 1996;53(9):814-24. [pmid: 8792758].
1084 Sackeim HA, Luber B, Moeller JR, Prudic J, Devanand DP, Nobler MS. Electrophysiological correlates of the adverse cognitive effects of electroconvulsive therapy. J Ect. Jun. 2000;16(2):110-20. [pmid: 10868321].
1085 Sackeim HA, Prudic J, Devanand DP, Decina P, Kerr B, Malitz S. The impact of medication resistance and continuation pharmacotherapy on relapse following response to electroconvulsive therapy in major depression. J Clin Psychopharmacol. Apr. 1990;10(2):96-104. [pmid: 2341598].
1086 Sackeim HA, Prudic J, Devanand DP, Kiersky JE, Fitzsimons L, Moody BJ, et al. Effects of stimulus intensity and electrode placement on the efficacy and cognitive effects of electroconvulsive therapy. N Engl J Med. Mar. 25. 1993;328(12):839-46. [pmid: 8441428].
1087 Sackeim HA, Prudic J, Fuller R, Keilp J, Lavori PW, Olfson M. The cognitive effects of electroconvulsive therapy in community settings. Neuropsychopharmacology. Jan. 2007;32(1):244-54. [pmid: 16936712].
1088 Sackeim HA, Rush AJ, George MS, Marangell LB, Husain MM, Nahas Z, et al. Vagus nerve stimulation (VNS) for treatment-resistant depression: efficacy, side effects, and predictors of outcome. Neuropsychopharmacology. Nov. 2001;25(5):713-28. [pmid: 11682255].
1089 Sagud M, Mihaljevic-Peles A, Muck-Seler D, Jakovljevic M, Pivac N. Quetiapine augmentation in treatment-resistant depression: a naturalistic study. Psychopharmacology (Berl). Sep. 2006;187(4):511-4. [pmid: 16802162].
1090 Saijo T, Takano A, Suhara T, Arakawa R, Okumura M, Ichimiya T, et al. Electroconvulsive therapy decreases dopamine D2 receptor binding in the anterior cingulate in patients with depression: a controlled study using positron emission tomography with radioligand [11C]FLB 457. J Clin Psychiatry. Jun. 2010;71(6):793-9. [pmid: 20021995].
1091 Saito S, Nishihara F, Akihiro T, Nishikawa K, Obata H, Goto F, et al. Landiolol and esmolol prevent tachycardia without altering cerebral blood flow. Can J Anaesth. Dec. 2005;52(10):1027-34. [pmid: 16326671].
1092 Saiz-Ruiz J, Ibanez A, Diaz-Marsa M, Arias F, Padin J, Martin-Carrasco M, et al. Efficacy of venlafaxine in major depression resistant to selective serotonin reuptake inhibitors. Prog Neuropsychopharmacol Biol Psychiatry. Oct. 2002;26(6):1129-34. [pmid: 12452535].
1093 Sajatovic M, DiGiovanni S, Fuller M, Belton J, DeVega E, Marqua S, et al. Nefazodone therapy in patients with treatment-resistant or treatment-intolerant depression and high psychiatric comorbidity. Clin Ther. Apr. 1999;21(4):733-40. [pmid: 10363738].
1094 Sakamoto A, Ogawa R, Suzuki H, Kimura M, Okubo Y, Fujiya T. Landiolol attenuates acute hemodynamic responses but does not reduce seizure duration during maintenance electroconvulsive therapy. Psychiatry Clin Neurosci. Dec. 2004;58(6):630-5. [pmid: 15601388].
1095 Salazar MR. Alpha lipoic acid: a novel treatment for depression. Med Hypotheses. Dec. 2000;55(6):510-2. [pmid: 11090300].
1096 Sanacora G, Fenton LR, Fasula MK, Rothman DL, Levin Y, Krystal JH, et al. Cortical gamma-aminobutyric acid concentrations in depressed patients receiving cognitive behavioral therapy. Biol Psychiatry. Feb. 1. 2006;59(3):284-6. [pmid: 16139814].
1097 Sanacora G, Kendell SF, Levin Y, Simen AA, Fenton LR, Coric V, et al. Preliminary evidence of riluzole efficacy in antidepressant-treated patients with residual depressive symptoms. Biol Psychiatry. Mar. 15. 2007;61(6):822-5. [pmid: 17141740].
1098 Sanacora G, Mason GF, Rothman DL, Hyder F, Ciarcia JJ, Ostroff RB, et al. Increased cortical GABA concentrations in depressed patients receiving ECT. Am J Psychiatry. Mar. 2003;160(3):577-9. [pmid: 12611844].
1099 Saravanan ES, Gangadhar BN, Janakiramaiah N, Pandey RS, Murthy HS, Subbakrishna DK. Does higher cardiovascular response to ECT predict early antidepressant effect?. J Affect Disord. May. 2002;69(1-3):101-8. [pmid: 12103457].
1100 Sartorius A, Henn FA. Deep brain stimulation of the lateral habenula in treatment resistant major depression. Med Hypotheses. 2007;69(6):1305-8. [pmid: 17498883].
1101 Satel SL, Nelson JC. Stimulants in the treatment of depression: a critical overview. J Clin Psychiatry. Jul. 1989;50(7):241-9. [pmid: 2567730].
1102 Sato Y, Yasui-Furukori N, Nakagami T, Saito M, Kaneko S. Augmentation of antidepressants with perospirone for treatment-resistant major depressive disorder. Prog Neuropsychopharmacol Biol Psychiatry. Apr. 30. 2009;33(3):416-8. [pmid: 19166896].
1103 Sawabini KA, Watts RL. Treatment of depression in Parkinson's disease. Parkinsonism Relat Disord. May. 1. 2004;10:S37-41. [pmid: 15109585].
1104 Sawayama E, Takahashi M, Inoue A, Nakajima K, Kano A, Sawayama T, et al. Moderate hyperventilation prolongs electroencephalogram seizure duration of the first electroconvulsive therapy. J Ect. Sep. 2008;24(3):195-8. [pmid: 18772703].
1105 Schachter SC. Vagus nerve stimulation: mood and cognitive effects. Epilepsy Behav. Feb. 1. 2004;5:S56-9. [pmid: 14725847].
1106 Schat A, van den Broek WW, Mulder PG, Birkenhager TK, van Tuijl R, Murre JM. Changes in everyday and semantic memory function after electroconvulsive therapy for unipolar depression. J Ect. Sep. 2007;23(3):153-7. [pmid: 17804988].
1107 Schechter LE, Ring RH, Beyer CE, Hughes ZA, Khawaja X, Malberg JE, et al. Innovative approaches for the development of antidepressant drugs: current and future strategies. NeuroRx. Oct. 2005;2(4):590-611. [pmid: 16489368].
1108 Schelde JT. Incomplete recovery among endogenously depressed patients: an ethological analysis. J Nerv Ment Dis. Jun. 2000;188(6):372-6. [pmid: 10890346].
1109 Schiffer F, Glass I, Lord J, Teicher MH. Prediction of clinical outcomes from rTMS in depressed patients with lateral visual field stimulation: a replication. J Neuropsychiatry Clin Neurosci. Spring. 2008;20(2):194-200. [pmid: 18451190].
1110 Schindler F, Anghelescu IG. Lithium versus lamotrigine augmentation in treatment resistant unipolar depression: a randomized, open-label study. Int Clin Psychopharmacol. May. 2007;22(3):179-82. [pmid: 17414745].
1111 Schlaepfer TE, Frick C, Zobel A, Maier W, Heuser I, Bajbouj M, et al. Vagus nerve stimulation for depression: efficacy and safety in a European study. Psychol Med. May. 2008;38(5):651-61. [pmid: 18177525].
1112 Schmauss M, Kapfhammer HP, Meyr P, Hoff P. Combined MAO-inhibitor and tri-(tetra) cyclic antidepressant treatment in therapy resistant depression. Prog Neuropsychopharmacol Biol Psychiatry. 1988;12(4):523-32. [pmid: 3406429].
1113 Schmauss M, Laakmann G, Dieterle D. Effects of alpha 2-receptor blockade in addition to tricyclic antidepressants in therapy-resistant depression. J Clin Psychopharmacol. Apr. 1988;8(2):108-11. [pmid: 3372705].
1114 Schopf J. Treatment of depressions resistant to tricyclic antidepressants, related drugs or MAO-inhibitors by lithium addition: review of the literature. Pharmacopsychiatry. Sep. 1989;22(5):174-82. [pmid: 2682691].
1115 Schopf J, Baumann P, Lemarchand T, Rey M. Treatment of endogenous depressions resistant to tricyclic antidepressants or related drugs by lithium addition. Results of a placebo-controlled double-blind study. Pharmacopsychiatry. Sep. 1989;22(5):183-7. [pmid: 2682692].
1116 Schopf J, Lemarchand T. Lithium addition in endogenous depressions resistant to tricyclic antidepressants or related drugs: relation to the status of the pituitary-thyroid axis. Pharmacopsychiatry. Sep. 1994;27(5):198-201. [pmid: 7838890].
1117 Schule C, Baghai TC, Eser D, Hecht S, Hermisson I, Born C, et al. Mirtazapine monotherapy versus combination therapy with mirtazapine and aripiprazole in depressed patients without psychotic features: a 4-week open-label parallel-group study. World J Biol Psychiatry. 2007;8(2):112-22. [pmid: 17455104].
1118 Schule C, Zwanzger P, Baghai T, Mikhaiel P, Thoma H, Moller HJ, et al. Effects of antidepressant pharmacotherapy after repetitive transcranial magnetic stimulation in major depression: an open follow-up study. J Psychiatr Res. Mar-Apr. 2003;37(2):145-53. [pmid: 12842168].
1119 Schultz SK, Anderson EA, van de Borne P. Heart rate variability before and after treatment with electroconvulsive therapy. J Affect Disord. Jun. 1997;44(1):13-20. [pmid: 9186798].
1120 Schulze-Rauschenbach SC, Harms U, Schlaepfer TE, Maier W, Falkai P, Wagner M. Distinctive neurocognitive effects of repetitive transcranial magnetic stimulation and electroconvulsive therapy in major depression. Br J Psychiatry. May. 2005;186:410-6. [pmid: 15863746].
1121 Schuster P, Opgenoorth E, Gabriel E, Presslich O, Sowinetz B. Results of learning experiments in the course of treatment of endogenomorphic depression. A comparison of electroconvulsive and pharmacological treatment. Psychopathology. 1986;19(3):116-30. [pmid: 3737823].
1122 Schutter DJ. Antidepressant efficacy of high-frequency transcranial magnetic stimulation over the left dorsolateral prefrontal cortex in double-blind sham-controlled designs: a meta-analysis. Psychol Med. Jan. 2009;39(1):65-75. [pmid: 18447962].
1123 Schweitzer I, Burrows G, Tuckwell V, Polonowita A, Flynn P, George T, et al. Sustained response to open-label venlafaxine in drug-resistant major depression. J Clin Psychopharmacol. Apr. 2001;21(2):185-9. [pmid: 11270915].
1124 Schweitzer I, Tuckwell V, Johnson G. A review of the use of augmentation therapy for the treatment of resistant depression: implications for the clinician. Aust N Z J Psychiatry. Jun. 1997;31(3):340-52. [pmid: 9226079].
1125 Scott AI, Boddy H. The effect of repeated bilateral electroconvulsive therapy on seizure threshold. J Ect. Sep. 2000;16(3):244-51. [pmid: 11005045].
1126 Scott AI, Rodger CR, Stocks RH, Shering AP. Is old-fashioned electroconvulsive therapy more efficacious? A randomised comparative study of bilateral brief-pulse and bilateral sine-wave treatments. Br J Psychiatry. Mar. 1992;160:360-4. [pmid: 1562862].
1127 Scott AI, Whalley LJ, Legros JJ. Treatment outcome, seizure duration, and the neurophysin response to ECT. Biol Psychiatry. Mar. 1. 1989;25(5):585-97. [pmid: 2920192].
1128 Scott J, Eccleston D, Boys R. Can we predict the persistence of depression?. Br J Psychiatry. Nov. 1992;161:633-7. [pmid: 1422613].
1129 Scott J, Palmer S, Paykel E, Teasdale J, Hayhurst H. Use of cognitive therapy for relapse prevention in chronic depression. Cost-effectiveness study. Br J Psychiatry. 2003:221-7.
1130 Scott TF, Allen D, Price TR, McConnell H, Lang D. Characterization of major depression symptoms in multiple sclerosis patients. J Neuropsychiatry Clin Neurosci. Summer. 1996;8(3):318-23. [pmid: 8854304].
1131 Seemuller F, Riedel M, Obermeier M, Bauer M, Adli M, Kronmuller K, et al. Outcomes of 1014 naturalistically treated inpatients with major depressive episode. Eur Neuropsychopharmacol. May. 2010;20(5):346-55. [pmid: 20097046].
1132 Segman RH, Shapira B, Gorfine M, Lerer B. Onset and time course of antidepressant action: psychopharmacological implications of a controlled trial of electroconvulsive therapy. Psychopharmacology (Berl). Jun. 1995;119(4):440-8. [pmid: 7480524].
1133 Seminowicz DA, Mayberg HS, McIntosh AR, Goldapple K, Kennedy S, Segal Z, et al. Limbic-frontal circuitry in major depression: a path modeling metanalysis. Neuroimage. May. 2004;22(1):409-18. [pmid: 15110034].
1134 Sensky T, Turkington D, Kingdon D, Scott JL, Scott J, Siddle R, et al. A randomized controlled trial of cognitive-behavioral therapy for persistent symptoms in schizophrenia resistant to medication. Arch Gen Psychiatry. Feb. 2000;57(2):165-72. [pmid: 10665619].
1135 Serretti A, Calati R, Massat I, Linotte S, Kasper S, Lecrubier Y, et al. Cytochrome P450 CYP1A2, CYP2C9, CYP2C19 and CYP2D6 genes are not associated with response and remission in a sample of depressive patients. Int Clin Psychopharmacol. Sep. 2009;24(5):250-6. [pmid: 19593158].
1136 Shah N, Mahadeshwar S, Bhakta S, Bhirud M, Fernandes P, Andrade C. The safety and efficacy of benzodiazepine-modified treatments as a special form of unmodified ECT. J ECT. Mar. 2010;26(1):23-9. [pmid: 20190597].
1137 Shajahan PM, Glabus MF, Gooding PA, Shah PJ, Ebmeier KP. Reduced cortical excitability in depression. Impaired post-exercise motor facilitation with transcranial magnetic stimulation. Br J Psychiatry. May. 1999;174:449-54. [pmid: 10616615].
1138 Shapira B, Cohen J, Newman ME, Lerer B. Prolactin response to fenfluramine and placebo challenge following maintenance pharmacotherapy withdrawal in remitted depressed patients. Biol Psychiatry. Apr. 1. 1993;33(7):531-5. [pmid: 8513038].
1139 Shapira B, Gorfine M, Lerer B. A prospective study of lithium continuation therapy in depressed patients who have responded to electroconvulsive therapy. Convuls Ther. Jun. 1995;11(2):80-5. [pmid: 7552058].
1140 Shapira B, Lerer B. Speed of response to bilateral ECT: an examination of possible predictors in two controlled trials. J Ect. Sep. 1999;15(3):202-6. [pmid: 10492858].
1141 Shapira B, Lerer B, Kindler S, Lichtenberg P, Gropp C, Cooper T, et al. Enhanced serotonergic responsivity following electroconvulsive therapy in patients with major depression. Br J Psychiatry. Feb. 1992;160:223-9. [pmid: 1540763].
1142 Shapira B, Lidsky D, Gorfine M, Lerer B. Electroconvulsive therapy and resistant depression: clinical implications of seizure threshold. J Clin Psychiatry. Jan. 1996;57(1):32-8. [pmid: 8543545].
1143 Shapira B, Nemets B, Trachtenberg A, Belmaker RH. Phenytoin as an augmentation for SSRI failures: a small controlled study. J Affect Disord. Nov. 2006;96(1-2):123-6. [pmid: 16814397].
1144 Shapira B, Oppenheim G, Zohar J, Segal M, Malach D, Belmaker RH. Lack of efficacy of estrogen supplementation to imipramine in resistant female depressives. Biol Psychiatry. May. 1985;20(5):576-9. [pmid: 2985131].
1145 Shapira B, Tubi N, Drexler H, Lidsky D, Calev A, Lerer B. Cost and benefit in the choice of ECT schedule. Twice versus three times weekly ECT. Br J Psychiatry. Jan. 1998;172:44-8. [pmid: 9534831].
1146 Shapira B, Tubi N, Lerer B. Balancing speed of response to ECT in major depression and adverse cognitive effects: role of treatment schedule. J Ect. Jun. 2000;16(2):97-109. [pmid: 10868320].
1147 Sharma R, Hedeker D, Pandey G, Janicak P, Davis J. A longitudinal study of plasma cortisol and depressive symptomatology by random regression analysis. Biol Psychiatry. Feb. 1. 1992;31(3):304-14. [pmid: 1547302].
1148 Sharma V. Treatment resistance in unipolar depression: Is it an iatrogenic phenomenon caused by antidepressant treatment of patients with a bipolar diathesis?. Med Hypotheses. 2006;67(5):1142-5. [pmid: 16797856].
1149 Sharma V, Khan M, Smith A. A closer look at treatment resistant depression: is it due to a bipolar diathesis?. J Affect Disord. Feb. 2005;84(2-3):251-7. [pmid: 15708423].
1150 Sharma V, Mazmanian D, Persad E, Kueneman K. A comparison of comorbid patterns in treatment-resistant unipolar and bipolar depression. Can J Psychiatry. Jun. 1995;40(5):270-4. [pmid: 7553547].
1151 Sharpley AL, Bhagwagar Z, Hafizi S, Whale WR, Gijsman HJ, Cowen PJ. Risperidone augmentation decreases rapid eye movement sleep and decreases wake in treatment-resistant depressed patients. J Clin Psychiatry. Feb. 2003;64(2):192-6. [pmid: 12633128].
1152 Shavitt RG, Valerio C, Fossaluza V, da Silva EM, Cordeiro Q, Diniz JB, et al. The impact of trauma and post-traumatic stress disorder on the treatment response of patients with obsessive-compulsive disorder. Eur Arch Psychiatry Clin Neurosci. Mar. 2010;260(2):91-9. [pmid: 20077119].
1153 Shaw DM. Pharmacological management of treatment-resistant depression. Psychopharmacol Ser. 1988;5:118-29. [pmid: 3045795].
1154 Shelton RC. Mood-stabilizing drugs in depression. J Clin Psychiatry. 5. 1999;60:37-40. discussion 1-2. [pmid: 10192406].
1155 Shelton RC. Treatment options for refractory depression. J Clin Psychiatry. 4. 1999;60:57-61. discussion 2-3. [pmid: 10086483].
1156 Shelton RC. The use of antidepressants in novel combination therapies. J Clin Psychiatry. 2. 2003;64:14-8. [pmid: 12625794].
1157 Shelton RC, Papakostas GI. Augmentation of antidepressants with atypical antipsychotics for treatment-resistant major depressive disorder. Acta Psychiatr Scand. Apr. 2008;117(4):253-9. [pmid: 18190674].
1158 Shelton RC, Tollefson GD, Tohen M, Stahl S, Gannon KS, Jacobs TG, et al. A novel augmentation strategy for treating resistant major depression. Am J Psychiatry. 2001:131-4.
1159 Shelton RC, Williamson DJ, Corya SA, Sanger TM, Van Campen LE, Case M, et al. Olanzapine/fluoxetine combination for treatment-resistant depression: a controlled study of SSRI and nortriptyline resistance. J Clin Psychiatry. 2005:1289-97.
1160 Shergill SS, Katona CL. Pharmacological choices after one antidepressant fails: a survey of UK psychiatrists. J Affect Disord. Mar. 1997;43(1):19-25. [pmid: 9127827].
1161 Shiah IS, Yatham LN, Srisurapanont M, Lam RW, Tam EM, Zis AP. Does the addition of pindolol accelerate the response to electroconvulsive therapy in patients with major depression? A double-blind, placebo-controlled pilot study. J Clin Psychopharmacol. Jun. 2000;20(3):373-8. [pmid: 10831027].
1162 Shirayama T, Sakamoto T, Sakatani T, Mani H, Yamamoto T, Matsubara H. Usefulness of paroxetine in depressed men with paroxysmal atrial fibrillation. Am J Cardiol. Jun. 15. 2006;97(12):1749-51. [pmid: 16765127].
1163 Shulman KI, Fischer HD, Herrmann N, Huo CY, Anderson GM, Rochon PA. Current prescription patterns and safety profile of irreversible monoamine oxidase inhibitors: a population-based cohort study of older adults. J Clin Psychiatry. Dec. 2009;70(12):1681-6. [pmid: 19852903].
1164 Sienaert P, Vansteelandt K, Demyttenaere K, Peuskens J. Randomized comparison of ultra-brief bifrontal and unilateral electroconvulsive therapy for major depression: cognitive side-effects. J Affect Disord. Apr. 2010;122(1-2):60-7. [pmid: 19577808].
1165 Sienaert PA, Vansteelandt K, Demyttenaere K, Peuskens J. Predictors of patient satisfaction after ultrabrief bifrontal and unilateral electroconvulsive therapies for major depression. J ECT. Mar. 2010;26(1):55-9. [pmid: 19458534].
1166 Silfverskiold P, Risberg J. Regional cerebral blood flow in depression and mania. Arch Gen Psychiatry. Mar. 1989;46(3):253-9. [pmid: 2563933].
1167 Silfverskiold P, Rosen I, Risberg J. Effects of electroconvulsive therapy on EEG and cerebral blood flow in depression. Eur Arch Psychiatry Neurol Sci. 1987;236(4):202-8. [pmid: 3582428].
1168 Simon JS, Nemeroff CB. Aripiprazole augmentation of antidepressants for the treatment of partially responding and nonresponding patients with major depressive disorder. J Clin Psychiatry. Oct. 2005;66(10):1216-20. [pmid: 16259533].
1169 Simpson GM, El Sheshai A, Rady A, Kingsbury SJ, Fayek M. Sertraline as monotherapy in the treatment of psychotic and nonpsychotic depression. J Clin Psychiatry. Aug. 2003;64(8):959-65. [pmid: 12927014].
1170 Simpson S, Baldwin RC, Jackson A, Burns A. The differentiation of DSM-III-R psychotic depression in later life from nonpsychotic depression: comparisons of brain changes measured by multispectral analysis of magnetic resonance brain images, neuropsychological findings, and clinical features. Biol Psychiatry. Jan. 15. 1999;45(2):193-204. [pmid: 9951567].
1171 Simpson S, Baldwin RC, Jackson A, Burns AS. Is subcortical disease associated with a poor response to antidepressants? Neurological, neuropsychological and neuroradiological findings in late-life depression. Psychol Med. Sep. 1998;28(5):1015-26. [pmid: 9794009].
1172 Sit D, Perel JM, Luther JF, Wisniewski SR, Helsel JC, Wisner KL. Disposition of chiral and racemic fluoxetine and norfluoxetine across childbearing. J Clin Psychopharmacol. Aug. 2010;30(4):381-6. [pmid: 20631556].
1173 Skolnick P, Popik P, Trullas R. Glutamate-based antidepressants: 20 years on. Trends Pharmacol Sci. Nov. 2009;30(11):563-9. [pmid: 19837463].
1174 Slotkin TA, Hays JC, Nemeroff CB, Carroll BJ. Dexamethasone suppression test identifies a subset of elderly depressed patients with reduced platelet serotonin transport and resistance to imipramine inhibition of transport. Depress Anxiety. 1997;6(1):19-25. [pmid: 9394871].
1175 Sluzewska A, Sobieska M, Rybakowski JK. Changes in acute-phase proteins during lithium potentiation of antidepressants in refractory depression. Neuropsychobiology. 1997;35(3):123-7. [pmid: 9170116].
1176 Small JG, Kellams JJ, Dennis JL, Milstein V. Comparison of molindone and tranylcypromine in the treatment of refractory depression. J Clin Pharmacol. Aug-Sep. 1981;21(8-9):351-8. [pmid: 7276229].
1177 Small JG, Small IF. Electroconvulsive therapy update. Psychopharmacol Bull. Oct. 1981;17(4):29-42. [pmid: 6280228].
1178 Smith DJ, Harrison N, Muir W, Blackwood DH. The high prevalence of bipolar spectrum disorders in young adults with recurrent depression: toward an innovative diagnostic framework. J Affect Disord. Feb. 2005;84(2-3):167-78. [pmid: 15708414].
1179 Smith GE, Rasmussen KG Jr, Cullum CM, Felmlee-Devine MD, Petrides G, Rummans TA, et al. A randomized controlled trial comparing the memory effects of continuation electroconvulsive therapy versus continuation pharmacotherapy: results from the Consortium for Research in ECT (CORE) study. J Clin Psychiatry. Feb. 2010;71(2):185-93. [pmid: 20193646].
1180 Smith M, Vogler J, Zarrouf F, Sheaves C, Jesse J. Electroconvulsive therapy: the struggles in the decision-making process and the aftermath of treatment. Issues Ment Health Nurs. Sep. 2009;30(9):554-9. [pmid: 19657869].
1181 Sneed JR, Roose SP, Keilp JG, Krishnan KR, Alexopoulos GS, Sackeim HA. Response inhibition predicts poor antidepressant treatment response in very old depressed patients. Am J Geriatr Psychiatry. Jul. 2007;15(7):553-63. [pmid: 17586780].
1182 Sobin C, Prudic J, Devanand DP, Nobler MS, Sackeim HA. Who responds to electroconvulsive therapy? A comparison of effective and ineffective forms of treatment. Br J Psychiatry. Sep. 1996;169(3):322-8. [pmid: 8879718].
1183 Sobin C, Sackeim HA, Prudic J, Devanand DP, Moody BJ, McElhiney MC. Predictors of retrograde amnesia following ECT. Am J Psychiatry. Jul. 1995;152(7):995-1001. [pmid: 7793470].
1184 Sokolski KN, Conney JC, Brown BJ, DeMet EM. Once-daily high-dose pindolol for SSRI-refractory depression. Psychiatry Res. Feb. 15. 2004;125(2):81-6. [pmid: 15006431].
1185 Solomon DA, Keller MB, Leon AC, Mueller TI, Lavori PW, Shea MT, et al. Multiple recurrences of major depressive disorder. Am J Psychiatry. Feb. 2000;157(2):229-33. [pmid: 10671391].
1186 Sommer BR, Satlin A, Friedman L, Cole JO. Glycopyrrolate versus atropine in post-ECT amnesia in the elderly. J Geriatr Psychiatry Neurol. Jan-Mar. 1989;2(1):18-21. [pmid: 2663013].
1187 Sonawalla SB, Fava M. Severe depression: is there a best approach?. CNS Drugs. 2001;15(10):765-76. [pmid: 11602003].
1188 Souery D, Amsterdam J, de Montigny C, Lecrubier Y, Montgomery S, Lipp O, et al. Treatment resistant depression: methodological overview and operational criteria. Eur Neuropsychopharmacol. Jan. 1999;9(1-2):83-91. [pmid: 10082232].
1189 Souery D, Oswald P, Massat I, Bailer U, Bollen J, Demyttenaere K, et al. Clinical factors associated with treatment resistance in major depressive disorder: results from a European multicenter study. J Clin Psychiatry. Jul. 2007;68(7):1062-70. [pmid: 17685743].
1190 Souery D, Papakostas GI, Trivedi MH. Treatment-resistant depression. J Clin Psychiatry. 6. 2006;67:16-22. [pmid: 16848672].
1191 Souery D, Van der Auwera K. The multiple facets of treatment-resistant depression. CNS Spectr. Nov. 2004;9(11):803-7. [pmid: 15520604].
1192 Spalletta G, Guida G, Caltagirone C. Is left stroke a risk-factor for selective serotonin reuptake inhibitor antidepressant treatment resistance?. J Neurol. Apr. 2003;250(4):449-55. [pmid: 12700911].
1193 Speer AM, Repella JD, Figueras S, Demian NK, Kimbrell TA, Wasserman EM, et al. Lack of adverse cognitive effects of 1 Hz and 20 Hz repetitive transcranial magnetic stimulation at 100% of motor threshold over left prefrontal cortex in depression. J Ect. Dec. 2001;17(4):259-63. [pmid: 11731727].
1194 Sperling W, Reulbach U, Kornhuber J. Clinical benefits and cost effectiveness of vagus nerve stimulation in a long-term treatment of patients with major depression. Pharmacopsychiatry. May. 2009;42(3):85-8. [pmid: 19452375].
1195 Spijker J, Nolen WA. An algorithm for the pharmacological treatment of depression. Acta Psychiatr Scand. Mar. 2010;121(3):180-9. [pmid: 19878134].
1196 Spronk D, Arns M, Bootsma A, van Ruth R, Fitzgerald PB. Long-term effects of left frontal rTMS on EEG and ERPs in patients with depression. Clin EEG Neurosci. Jul. 2008;39(3):118-24. [pmid: 18751560].
1197 Squire LR, Slater PC. Electroconvulsive therapy and complaints of memory dysfunction: a prospective three-year follow-up study. Br J Psychiatry. Jan. 1983;142:1-8. [pmid: 6831121].
1198 St John D. Pharmacotherapeutic approaches to treatment-resistant depression. Jaapa. Mar. 2003;16(3):32-4. 7. 8. 40 passim. [pmid: 14968524].
1199 Stain-Malmgren R, Khoury AE, Aberg-Wistedt A, Tham A. Serotonergic function in major depression and effect of sertraline and paroxetine treatment. Int Clin Psychopharmacol. Mar. 2001;16(2):93-101. [pmid: 11236074].
1200 Standish-Barry H. Treating refractory depression. Int Clin Psychopharmacol. Jul. 3. 1990;5:33-43. [pmid: 2230071].
1201 Staroverov AT, Zhukov OB, Raigorodskii YM. Efficacy of transcranial magnetotherapy in the complex treatment of alcohol withdrawal syndrome. Neurosci Behav Physiol. Nov. 2009;39(9):891-5. [pmid: 19830574].
1202 Steen A, Den Boer JA. A double-blind six months comparative study of milnacipran and clomipramine in major depressive disorder. Int Clin Psychopharmacol. Sep. 1997;12(5):269-81. [pmid: 9466161].
1203 Steffens DC, McQuoid DR, Krishnan KR. The Duke Somatic Treatment Algorithm for Geriatric Depression (STAGED) approach. Psychopharmacol Bull. Spring. 2002;36(2):58-68. [pmid: 12397841].
1204 Steffens DC, Pieper CF, Bosworth HB, MacFall JR, Provenzale JM, Payne ME, et al. Biological and social predictors of long-term geriatric depression outcome. Int Psychogeriatr. Mar. 2005;17(1):41-56. [pmid: 15948303].
1205 Stein MB, Kline NA, Matloff JL. Adjunctive olanzapine for SSRI-resistant combat-related PTSD: a double-blind, placebo-controlled study. Am J Psychiatry. Oct. 2002;159(10):1777-9. [pmid: 12359687].
1206 Stek ML, Van der Wurff FB, Hoogendijk WL, Beekman AT. Electroconvulsive therapy for the depressed elderly. Cochrane Database Syst Rev. 2003;(2). CD003593.
1207 Stek ML, Van Exel E, Van Tilburg W, Westendorp RG, Beekman AT. The prognosis of depression in old age: outcome six to eight years after clinical treatment. Aging Ment Health. Aug. 2002;6(3):282-5. [pmid: 12217097].
1208 Stern RA, Nevels CT, Shelhorse ME, Prohaska ML, Mason GA, Prange AJ Jr. Antidepressant and memory effects of combined thyroid hormone treatment and electroconvulsive therapy: preliminary findings. Biol Psychiatry. Sep. 15. 1991;30(6):623-7. [pmid: 1932410].
1209 Stern SL, Mendels J. Drug combinations in the treatment of refractory depression: a review. J Clin Psychiatry. Oct. 1981;42(10):368-73. [pmid: 6116699].
1210 Stern WC, Harto-Truax N, Bauer N. Efficacy of bupropion in tricyclic-resistant or intolerant patients. J Clin Psychiatry. May. 1983;44(5 Pt 2):148-52. [pmid: 6406447].
1211 Stewart JW, McGrath PJ, Quitkin FM. Do age of onset and course of illness predict different treatment outcome among DSM IV depressive disorders with atypical features?. Neuropsychopharmacology. Feb. 2002;26(2):237-45. [pmid: 11790519].
1212 Stiebel VG. Maintenance electroconvulsive therapy for chronic mentally ill patients: a case series. Psychiatr Serv. Mar. 1995;46(3):265-8. [pmid: 7796215].
1213 Stoppe A, Louza M, Rosa M, Gil G, Rigonatti S. Fixed high-dose electroconvulsive therapy in the elderly with depression: a double-blind, randomized comparison of efficacy and tolerability between unilateral and bilateral electrode placement. J Ect. Jun. 2006;22(2):92-9. [pmid: 16801822].
1214 Stoudemire A. Expanding psychopharmacologic treatment options for the depressed medical patient. Psychosomatics. Mar-Apr. 1995;36(2):S19-26. [pmid: 7724709].
1215 Stoudemire A, Hill CD, Dalton ST, Marquardt MG. Rehospitalization rates in older depressed adults after antidepressant and electroconvulsive therapy treatment. J Am Geriatr Soc. Dec. 1994;42(12):1282-5. [pmid: 7983293].
1216 Stoudemire A, Hill CD, Marquardt M, Dalton S, Lewison BJ. Recovery and relapse in geriatric depression after treatment with antidepressants and ECT in a medical-psychiatric population. Gen Hosp Psychiatry. May. 1998;20(3):170-4. [pmid: 9650035].
1217 Stoudemire A, Hill CD, Morris R, Lewison BJ. Long-term outcome of treatment-resistant depression in older adults. Am J Psychiatry. Oct. 1993;150(10):1539-40. [pmid: 8379561].
1218 Stoudemire A, Hill CD, Morris R, Martino-Saltzman D, Lewison B. Long-term affective and cognitive outcome in depressed older adults. Am J Psychiatry. Jun. 1993;150(6):896-900. [pmid: 8494065].
1219 Stoudemire A, Hill CD, Morris R, Martino-Saltzman D, Markwalter H, Lewison B. Cognitive outcome following tricyclic and electroconvulsive treatment of major depression in the elderly. Am J Psychiatry. Oct. 1991;148(10):1336-40. [pmid: 1897613].
1220 Stoudemire A, Knos G, Gladson M, Markwalter H, Sung YF, Morris R, et al. Labetalol in the control of cardiovascular responses to electroconvulsive therapy in high-risk depressed medical patients. J Clin Psychiatry. Dec. 1990;51(12):508-12. [pmid: 2258364].
1221 Strunk DR, Stewart MO, Hollon SD, DeRubeis RJ, Fawcett J, Amsterdam JD, et al. Can pharmacotherapists be too supportive? A process study of active medication and placebo in the treatment of depression. Psychol Med. Aug. 2010;40(8):1379-87. [pmid: 19891806].
1222 Stryjer R, Strous RD, Shaked G, Bar F, Feldman B, Kotler M, et al. Amantadine as augmentation therapy in the management of treatment-resistant depression. Int Clin Psychopharmacol. Mar. 2003;18(2):93-6. [pmid: 12598820].
1223 Sunderland T, Cohen RM, Molchan S, Lawlor BA, Mellow AM, Newhouse PA, et al. High-dose selegiline in treatment-resistant older depressive patients. Arch Gen Psychiatry. 1994/08/01. 1994:607-15.
1224 Suominen KH, Isometsa ET, Henriksson MM, Ostamo AI, Lonnqvist JK. Inadequate treatment for major depression both before and after attempted suicide. Am J Psychiatry. Dec. 1998;155(12):1778-80. [pmid: 9842794].
1225 Surtees PG, Barkley C. Future imperfect: the long-term outcome of depression. Br J Psychiatry. Mar. 1994;164(3):327-41. [pmid: 8199786].
1226 Swan J, Sorrell E, MacVicar B, Durham R, Matthews K. “Coping with depression”: an open study of the efficacy of a group psychoeducational intervention in chronic, treatment-refractory depression. J Affect Disord. Oct. 1. 2004;82(1):125-9. [pmid: 15465585].
1227 Swartz CM, Morrow V, Surles L, James JF. Long-term outcome after ECT for catatonic depression. J Ect. Sep. 2001;17(3):180-3. [pmid: 11528308].
1228 Swoboda E, Conca A, Konig P, Waanders R, Hansen M. Maintenance electroconvulsive therapy in affective and schizoaffective disorder. Neuropsychobiology. Jan. 2001;43(1):23-8. [pmid: 11150895].
1229 Szuba MP, O'Reardon JP, Rai AS, Snyder-Kastenberg J, Amsterdam JD, Gettes DR, et al. Acute mood and thyroid stimulating hormone effects of transcranial magnetic stimulation in major depression. Biol Psychiatry. Jul. 1. 2001;50(1):22-7. [pmid: 11457420].
1230 Tajima O. Japanese experience with dual-action antidepressants. Int Clin Psychopharmacol. Jun. 1. 2002;17:S37-42. [pmid: 12369609].
1231 Takahashi H, Kamata M, Yoshida K, Higuchi H, Ishigooka J. Augmentation with olanzapine in TCA-refractory depression with melancholic features: a consecutive case series. Hum Psychopharmacol. Apr. 2008;23(3):217-20. [pmid: 18172909].
1232 Takahashi S, Mizukami K, Yasuno F, Asada T. Depression associated with dementia with Lewy bodies (DLB) and the effect of somatotherapy. Psychogeriatrics. 2009/07/17. 2009:56-61.
1233 Talbot NL, Conwell Y, O'Hara MW, Stuart S, Ward EA, Gamble SA, et al. Interpersonal psychotherapy for depressed women with sexual abuse histories: a pilot study in a community mental health center. J Nerv Ment Dis. Dec. 2005;193(12):847-50. [pmid: 16319710].
1234 Tam W, Young JP, John G, Lader MH. A controlled comparison of flupenthixol decanoate injections and oral amitriptyline in depressed out-patients. Br J Psychiatry. Mar. 1982;140:287-91. [pmid: 7093597].
1235 Tang WK, Ungvari GS, Leung HC. Effect of piracetam on ECT-induced cognitive disturbances: a randomized, placebo-controlled, double-blind study. J Ect. Sep. 2002;18(3):130-7. [pmid: 12394531].
1236 Tanum LH. Combination treatment with antidepressants in refractory depression. Int Clin Psychopharmacol. Jun. 2. 1994;9:37-40. [pmid: 7930495].
1237 Targum SD, Greenberg RD, Harmon RL, Kessler K, Salerian AJ, Fram DH. Thyroid hormone and the TRH stimulation test in refractory depression. J Clin Psychiatry. Aug. 1984;45(8):345-6. [pmid: 6746579].
1238 Taylor D. Selective serotonin reuptake inhibitors and tricyclic antidepressants in combination. Interactions and therapeutic uses. Br J Psychiatry. Nov. 1995;167(5):575-80. [pmid: 8564311].
1239 Taylor SM. Electroconvulsive therapy, brain-derived neurotrophic factor, and possible neurorestorative benefit of the clinical application of electroconvulsive therapy. J Ect. Jun. 2008;24(2):160-5. [pmid: 18580563].
1240 Tedlow J, Fava M, Uebelacker L, Nierenberg AA, Alpert JE, Rosenbaum J. Outcome definitions and predictors in depression. Psychother Psychosom. Jul-Oct. 1998;67(4-5):266-70. [pmid: 9693355].
1241 Telner JI, Singhal RL. Psychiatric progress. The learned helplessness model of depression. J Psychiatr Res. 1984;18(3):207-15. [pmid: 6492008].
1242 Tew JD Jr, Mulsant BH, Haskett RF, Dolata D, Hixson L, Mann JJ. A randomized comparison of high-charge right unilateral electroconvulsive therapy and bilateral electroconvulsive therapy in older depressed patients who failed to respond to 5 to 8 moderate-charge right unilateral treatments. J Clin Psychiatry. Dec. 2002;63(12):1102-5. [pmid: 12523868].
1243 Tew JD Jr, Mulsant BH, Haskett RF, Joan P, Begley AE, Sackeim HA. Relapse during continuation pharmacotherapy after acute response to ECT: a comparison of usual care versus protocolized treatment. Ann Clin Psychiatry. Jan-Mar. 2007;19(1):1-4. [pmid: 17453654].
1244 Tew JD Jr, Mulsant BH, Haskett RF, Prudic J, Thase ME, Crowe RR, et al. Acute efficacy of ECT in the treatment of major depression in the old-old. Am J Psychiatry. Dec. 1999;156(12):1865-70. [pmid: 10588398].
1245 Tew JD Jr, Mulsant BH, Houck PR, Lenze EJ, Whyte EM, Miller MD, et al. Impact of prior treatment exposure on response to antidepressant treatment in late life. Am J Geriatr Psychiatry. Nov. 2006;14(11):957-65. [pmid: 17068318].
1246 Thase ME. Long-term treatments of recurrent depressive disorders. J Clin Psychiatry. Sep. Suppl. 1992;53:32-44. [pmid: 1522078].
1247 Thase ME. The role of Axis II comorbidity in the management of patients with treatment-resistant depression. Psychiatr Clin North Am. Jun. 1996;19(2):287-309. [pmid: 8827191].
1248 Thase ME. Psychotherapy of refractory depressions. Depress Anxiety. 1997;5(4):190-201. [pmid: 9338111].
1249 Thase ME. The need for clinically relevant research on treatment-resistant depression. J Clin Psychiatry. Apr. 2001;62(4):221-4. [pmid: 11379833].
1250 Thase ME. What role do atypical antipsychotic drugs have in treatment-resistant depression?. J Clin Psychiatry. Feb. 2002;63(2):95-103. [pmid: 11874227].
1251 Thase ME. New approaches to managing difficult-to-treat depressions. J Clin Psychiatry. 1. 2003;64:3-4.
1252 Thase ME. Therapeutic alternatives for difficult-to-treat depression: a narrative review of the state of the evidence. CNS Spectr. Nov. 2004;9(11):808-16. 18. 21. [pmid: 15520605].
1253 Thase ME. Bipolar depression: issues in diagnosis and treatment. Harv Rev Psychiatry. Sep-Oct. 2005;13(5):257-71. [pmid: 16251165].
1254 Thase ME. Management of patients with treatment-resistant depression. J Clin Psychiatry. Mar. 2008;69(3):e8. [pmid: 18402495].
1255 Thase ME. Pharmacotherapeutic treatment strategies for antidepressant nonresponse. J Clin Psychiatry. Nov. 2009;70(11):e42. [pmid: 20031090].
1256 Thase ME. Evaluating atypical antipsychotics in the treatment of refractory depression. J Clin Psychiatry. May. 2009;70(5):e14. [pmid: 19552861].
1257 Thase ME. Pharmacologic and therapeutic strategies in treatment-resistant depression. Augmentation strategies. CNS Spectr. Mar. 2009;14(3 Suppl 4):7-10. [pmid: 19407714].
1258 Thase ME, Frank E, Mallinger AG, Hamer T, Kupfer DJ. Treatment of imipramine-resistant recurrent depression, III: Efficacy of monoamine oxidase inhibitors. J Clin Psychiatry. Jan. 1992;53(1):5-11. [pmid: 1737741].
1259 Thase ME, Friedman ES, Howland RH. Venlafaxine and treatment-resistant depression. Depress Anxiety. 1. 2000;12:55-62. [pmid: 11098415].
1260 Thase ME, Friedman ES, Howland RH. Management of treatment-resistant depression: psychotherapeutic perspectives. J Clin Psychiatry. 18. 2001;62:18-24.
1261 Thase ME, Howland RH, Friedman ES. Treating antidepressant nonresponders with augmentation strategies: an overview. J Clin Psychiatry. 5. 1998;59:5-12. discussion 3-5. [pmid: 9635543].
1262 Thase ME, Kupfer DJ, Frank E, Jarrett DB. Treatment of imipramine-resistant recurrent depression: II. An open clinical trial of lithium augmentation. J Clin Psychiatry. Nov. 1989;50(11):413-7. [pmid: 2509437].
1263 Thase ME, Kupfer DJ, Jarrett DB. Treatment of imipramine-resistant recurrent depression: I. An open clinical trial of adjunctive L-triiodothyronine. J Clin Psychiatry. Oct. 1989;50(10):385-8. [pmid: 2676995].
1264 Thase ME, Rush AJ. When at first you don't succeed: sequential strategies for antidepressant nonresponders. J Clin Psychiatry. 13. 1997;58:23-9. [pmid: 9402916].
1265 Thase ME, Rush AJ, Howland RH, Kornstein SG, Kocsis JH, Gelenberg AJ, et al. Double-blind switch study of imipramine or sertraline treatment of antidepressant-resistant chronic depression. Arch Gen Psychiatry. Mar. 2002;59(3):233-9. [pmid: 11879161].
1266 Thase ME, Sachs GS. Bipolar depression: pharmacotherapy and related therapeutic strategies. Biol Psychiatry. Sep. 15. 2000;48(6):558-72. [pmid: 11018227].
1267 Thase ME, Shelton RC, Khan A. Treatment with venlafaxine extended release after SSRI nonresponse or intolerance: a randomized comparison of standard- and higher-dosing strategies. J Clin Psychopharmacol. Jun. 2006;26(3):250-8. [pmid: 16702889].
1268 Theodorou AE, Katona CL, Davies SL, Hale AS, Kerry SM, Horton RW, et al. 3H-imipramine binding to freshly prepared platelet membranes in depression. Psychiatry Res. Jul. 1989;29(1):87-103. [pmid: 2549556].
1269 Thienhaus OJ, Margletta S, Bennett JA. A study of the clinical efficacy of maintenance ECT. J Clin Psychiatry. Apr. 1990;51(4):141-4. [pmid: 2324077].
1270 Thompson C, Thompson CM. Treatment resistant or irresolutely treated. Int Clin Psychopharmacol. Jul. 1. 1991;6:31-8. discussion 8-9. [pmid: 1757717].
1271 Tielkes CE, Comijs HC, Verwijk E, Stek ML. The effects of ECT on cognitive functioning in the elderly: a review. Int J Geriatr Psychiatry. Aug. 2008;23(8):789-95. [pmid: 18311845].
1272 Tierney JG. Treatment-resistant depression: managed care considerations. J Manag Care Pharm. Jul. 2007;13(6 Suppl A):S2-7. [pmid: 17672818].
1273 Tobin M. Psychopharmacology column: why choose selegiline transdermal system for refractory depression?. Issues Ment Health Nurs. Feb. 2007;28(2):223-8. [pmid: 17365170].
1274 Tremblay P, Blier P. Catecholaminergic strategies for the treatment of major depression. Curr Drug Targets. Feb. 2006;7(2):149-58. [pmid: 16475956].
1275 Tribo MJ, Andion O, Ros S, Gilaberte M, Gallardo F, Toll A, et al. Clinical characteristics and psychopathological profile of patients with vulvodynia: an observational and descriptive study. Dermatology. 2008;216(1):24-30. [pmid: 18032895].
1276 Triezenberg D, Vachon D, Helmen J, Schneider D. Clinical inquiries: How should you manage a depressed patient unresponsive to an SSRI. J Fam Pract. Dec. 2006;55(12):1081-2. 7. [pmid: 17137547].
1277 Triggs WJ, Ricciuti N, Ward HE, Cheng J, Bowers D, Goodman WK, et al. Right and left dorsolateral pre-frontal rTMS treatment of refractory depression: a randomized, sham-controlled trial. Psychiatry Res. 2010/07/21. 2010:467-74.
1278 Trimble MR. Worldwide use of clomipramine. J Clin Psychiatry. Aug. Suppl. 1990;51:51-4. discussion 5-8. [pmid: 2199435].
1279 Trivedi MH. Treatment-resistant depression: new therapies on the horizon. Ann Clin Psychiatry. Mar. 2003;15(1):59-70. [pmid: 12839433].
1280 Trivedi MH, Daly EJ. Treatment strategies to improve and sustain remission in major depressive disorder. Dialogues Clin Neurosci. 2008;10(4):377-84. [pmid: 19170395].
1281 Trivedi MH, Kleiber BA. Using treatment algorithms for the effective management of treatment-resistant depression. J Clin Psychiatry. 18. 2001;62:25-9. [pmid: 11575732].
1282 Trivedi MH, Lin EH, Katon WJ. Consensus recommendations for improving adherence, self-management, and outcomes in patients with depression. CNS Spectr. Aug. 2007;12(8 Suppl 13):1-27. [pmid: 17986951].
1283 Trivedi MH, Rush AJ, Crismon ML, Kashner TM, Toprac MG, Carmody TJ, et al. Clinical results for patients with major depressive disorder in the Texas Medication Algorithm Project. Arch Gen Psychiatry. Jul. 2004;61(7):669-80. [pmid: 15237079].
1284 Trivedi MH, Thase ME, Osuntokun O, Henley DB, Case M, Watson SB, et al. An integrated analysis of olanzapine/fluoxetine combination in clinical trials of treatment-resistant depression. J Clin Psychiatry. Mar. 2009;70(3):387-96. [pmid: 19284928].
1285 Tsai SJ. Possible involvement of the BDNF-dependent pathway in treatment-emergent suicidality or decreased response to antidepressants. Med Hypotheses. 2005;65(5):942-6. [pmid: 16002234].
1286 Tsai SJ. Sipatrigine could have therapeutic potential for major depression and bipolar depression through antagonism of the two-pore-domain K+ channel TREK-1. Med Hypotheses. 2008;70(3):548-50. [pmid: 17703894].
1287 Tsourtos G, Spong J, Stough C. The effects of electro-convulsive therapy on the speed of information processing in major depression. J Affect Disord. Nov. 2007;103(1-3):263-6. [pmid: 17328957].
1288 Tsuchiyama K, Nagayama H, Yamada K, Isogawa K, Katsuragi S, Kiyota A. Predicting efficacy of electroconvulsive therapy in major depressive disorder. Psychiatry Clin Neurosci. Oct. 2005;59(5):546-50. [pmid: 16194256].
1289 Turkewitz LJ, Casaly JS, Dawson GA, Wirth O. Phenelzine therapy for headache patients with concomitant depression and anxiety. Headache. Apr. 1992;32(4):203-7. [pmid: 1582841].
1290 Turner TH, Ur E, Grossman A. Naloxone has no effect on hormonal responses to ECT in man. Psychiatry Res. Nov. 1987;22(3):207-12. [pmid: 2829259].
1291 Turnier-Shea Y, Bruno R, Pridmore S. Daily and spaced treatment with transcranial magnetic stimulation in major depression: a pilot study. Aust N Z J Psychiatry. Sep. 2006;40(9):759-63. [pmid: 16911750].
1292 Udupa K, Sathyaprabha TN, Thirthalli J, Kishore KR, Raju TR, Gangadhar BN. Modulation of cardiac autonomic functions in patients with major depression treated with repetitive transcranial magnetic stimulation. J Affect Disord. Dec. 2007;104(1-3):231-6. [pmid: 17490754].
1293 Uhlmann C, Froscher W. Biofeedback treatment in patients with refractory epilepsy: changes in depression and control orientation. Seizure. Jan. 2001;10(1):34-8. [pmid: 11181095].
1294 Vakili K, Pillay SS, Lafer B, Fava M, Renshaw PF, Bonello-Cintron CM, et al. Hippocampal volume in primary unipolar major depression: a magnetic resonance imaging study. Biol Psychiatry. Jun. 15. 2000;47(12):1087-90. [pmid: 10862809].
1295 van Beusekom BS, van den Broek WW, Birkenhager TK. Long-term follow-up after successful electroconvulsive therapy for depression: a 4- to 8-year naturalistic follow-up study. J Ect. Mar. 2007;23(1):17-20. [pmid: 17435567].
1296 van den Broek WW, Birkenhager TK, Mulder PG, Bruijn JA, Moleman P. Imipramine is effective in preventing relapse in electroconvulsive therapy-responsive depressed inpatients with prior pharmacotherapy treatment failure: a randomized, placebo-controlled trial. J Clin Psychiatry. Feb. 2006;67(2):263-8. [pmid: 16566622].
1297 van den Broek WW, de Lely A, Mulder PG, Birkenhager TK, Bruijn JA. Effect of antidepressant medication resistance on short-term response to electroconvulsive therapy. J Clin Psychopharmacol. Aug. 2004;24(4):400-3. [pmid: 15232331].
1298 van den Broek WW, Groenland TH, Kusuma A, Mulder PG, Bruijn JA. Double-blind placebo controlled study of the effects of etomidate-alfentanil anesthesia in electroconvulsive therapy. J Ect. Jun. 2004;20(2):107-11. [pmid: 15167427].
1299 Van der Does AJ, Booij L. Cognitive therapy does not prevent a response to tryptophan depletion in patients also treated with antidepressants. Biol Psychiatry. Dec. 1. 2005;58(11):913-5. [pmid: 16039618].
1300 van Hiele LJ. l-5-Hydroxytryptophan in depression: the first substitution therapy in psychiatry? The treatment of 99 out-patients with ‘therapy-resistant’ depressions. Neuropsychobiology. 1980;6(4):230-40. [pmid: 6967194].
1301 Van HL, Dekker J, Peen J, van Aalst G, Schoevers RA. Identifying patients at risk of complete nonresponse in the outpatient treatment of depression. Psychother Psychosom. 2008;77(6):358-64. [pmid: 18701832].
1302 Van Hunsel F, Wauters A, Vandoolaeghe E, Neels H, Demedts P, Maes M. Lower total serum protein, albumin, and beta- and gamma-globulin in major and treatment-resistant depression: effects of antidepressant treatments. Psychiatry Res. Dec. 20. 1996;65(3):159-69. [pmid: 9029664].
1303 van Praag HM. Serotonin precursors in the treatment of depression. Adv Biochem Psychopharmacol. 1982;34:259-86. [pmid: 6753514].
1304 Vanderhasselt MA, De Raedt R, Baeken C, Leyman L, D'Haenen H. A single session of rTMS over the left dorsolateral prefrontal cortex influences attentional control in depressed patients. World J Biol Psychiatry. 2009;10(1):34-42. [pmid: 19673086].
1305 Vanderhasselt MA, De Raedt R, Leyman L, Baeken C. Acute effects of repetitive transcranial magnetic stimulation on attentional control are related to antidepressant outcomes. J Psychiatry Neurosci. Mar. 2009;34(2):119-26. [pmid: 19270762].
1306 Vanelle JM, Loo H, Galinowski A, de Carvalho W, Bourdel MC, Brochier P, et al. Maintenance ECT in intractable manic-depressive disorders. Convuls Ther. Sep. 1994;10(3):195-205. [pmid: 7834256].
1307 Vasudev K, Macritchie K, Geddes J, Watson S, Young A. Topiramate for acute affective episodes in bipolar disorder. Cochrane Database Syst Rev. 2006;(1). CD003384.
1308 Vlissides DN, Jenner FA. The response of endogenously and reactivity depressed patients to electroconvulsive therapy. Br J Psychiatry. Sep. 1982;141:239-42. [pmid: 7139205].
1309 Volz HP, Faltus F, Magyar I, Moller HJ. Brofaromine in treatment-resistant depressed patients--a comparative trial versus tranylcypromine. J Affect Disord. Mar. 1994;30(3):209-17. [pmid: 8006247].
1310 Vonck K, Dedeurwaerdere S, De Groote L, Thadani V, Claeys P, Gossiaux F, et al. Generator replacement in epilepsy patients treated with vagus nerve stimulation. Seizure. Mar. 2005;14(2):89-99. [pmid: 15694561].
1311 Vothknecht S, Kho KH, van Schaick HW, Zwinderman AH, Middelkoop H, Blansjaar BA. Effects of maintenance electroconvulsive therapy on cognitive functions. J Ect. Sep. 2003;19(3):151-7. [pmid: 12972985].
1312 Wager SG, Klein DF. Drug therapy strategies for treatment-resistant depression. Psychopharmacol Bull. 1988;24(1):69-74. [pmid: 3290951].
1313 Wagner A, Aberg-Wistedt A, Asberg M, Bertilsson L, Martensson B, Montero D. Effects of antidepressant treatments on platelet tritiated imipramine binding in major depressive disorder. Arch Gen Psychiatry. Oct. 1987;44(10):870-7. [pmid: 2821953].
1314 Wagner J, Allen NA, Swalley LM, Melkus GD, Whittemore R. Depression, depression treatment, and insulin sensitivity in adults at risk for type 2 diabetes. Diabetes Res Clin Pract. Nov. 2009;86(2):96-103. [pmid: 19720419].
1315 Wajima Z, Yoshikawa T, Ogura A, Shiga T, Inoue T, Ogawa R. The effects of intravenous lignocaine on haemodynamics and seizure duration during electroconvulsive therapy. Anaesth Intensive Care. Dec. 2002;30(6):742-6. [pmid: 12500511].
1316 Walderhaug E, Kasserman S, Aikins D, Vojvoda D, Nishimura C, Neumeister A. Effects of duloxetine in treatment-refractory men with posttraumatic stress disorder. Pharmacopsychiatry. Mar. 2010;43(2):45-9. [pmid: 20108200].
1317 Walpoth M, Hoertnagl C, Mangweth-Matzek B, Kemmler G, Hinterholzl J, Conca A, et al. Repetitive transcranial magnetic stimulation in bulimia nervosa: preliminary results of a single-centre, randomised, double-blind, sham-controlled trial in female outpatients. Psychother Psychosom. 2008;77(1):57-60. [pmid: 18087209].
1318 Walter G, Martin J, Kirkby K, Pridmore S. Transcranial magnetic stimulation: experience, knowledge and attitudes of recipients. Aust N Z J Psychiatry. Feb. 2001;35(1):58-61. [pmid: 11270457].
1319 Wan DD, Kundhur D, Solomons K, Yatham LN, Lam RW. Mirtazapine for treatment-resistant depression: a preliminary report. J Psychiatry Neurosci. Jan. 2003;28(1):55-9. [pmid: 12587851].
1320 Wang Y, Fang YR, Chen XS, Chen J, Wu ZG, Yuan CM, et al. A follow-up study on features of sensory gating P50 in treatment-resistant depression patients. Chin Med J (Engl). Dec. 2009;122(24):2956-60. [pmid: 20137481].
1321 Warneke L. Managing resistant depression. When patients do not respond to therapy. Can Fam Physician. Apr. 1993;39:843-50. [pmid: 8495142].
1322 Warneke L. Management of resistant depression. Can Fam Physician. Oct. 1996;42:1973-80. [pmid: 8894244].
1323 Warren EW, Groome DH. Memory test performance under three different waveforms of ECT for depression. Br J Psychiatry. Apr. 1984;144:370-5. [pmid: 6722398].
1324 Watkins E, Scott J, Wingrove J, Rimes K, Bathurst N, Steiner H, et al. Rumination-focused cognitive behaviour therapy for residual depression: a case series. Behav Res Ther. Sep. 2007;45(9):2144-54. [pmid: 17367751].
1325 Weber-Hamann B, Gilles M, Lederbogen F, Heuser I, Deuschle M. Improved insulin sensitivity in 80 nondiabetic patients with MDD after clinical remission in a double-blind, randomized trial of amitriptyline and paroxetine. J Clin Psychiatry. Dec. 2006;67(12):1856-61. [pmid: 17194262].
1326 Weintraub D. Nortriptyline in geriatric depression resistant to serotonin reuptake inhibitors: case series. J Geriatr Psychiatry Neurol. Spring. 2001;14(1):28-32. [pmid: 11281313].
1327 Weisler RH. How do you choose a second-line treatment option for depression?. J Clin Psychiatry. 1. 2010;71:21-6. [pmid: 20977872].
1328 Wells DG, Davies GG, Rosewarne F. Attenuation of electroconvulsive therapy induced hypertension with sublingual nifedipine. Anaesth Intensive Care. Feb. 1989;17(1):31-3. [pmid: 2712272].
1329 Wells-Parker E, Dill P, Williams M, Stoduto G. Are depressed drinking/driving offenders more receptive to brief intervention?. Addict Behav. Feb. 2006;31(2):339-50. [pmid: 16005159].
1330 Wesner RB, Winokur G. An archival study of depression before and after age 55. J Geriatr Psychiatry Neurol. Oct-Dec. 1988;1(4):220-5. [pmid: 3252889].
1331 Wesner RB, Winokur G. The influence of age on the natural history of unipolar depression when treated with electroconvulsive therapy. Eur Arch Psychiatry Neurol Sci. 1989;238(3):149-54. [pmid: 2721532].
1332 Wesson ML, Wilkinson AM, Anderson DN, Cracken CM. Does age predict the long-term outcome of depression treated with ECT? (a prospective study of the long-term outcome of ECT-treated depression with respect to age). Int J Geriatr Psychiatry. Jan. 1997;12(1):45-51. [pmid: 9050423].
1333 West ED. Electric convulsion therapy in depression: a double-blind controlled trial. Br Med J (Clin Res Ed). 1981:355-7.
1334 White K, Simpson G. Combined MAOI-tricyclic antidepressant treatment: a reevaluation. J Clin Psychopharmacol. Sep. 1981;1(5):264-82. [pmid: 7037873].
1335 White K, Wykoff W, Tynes LL, Schneider L, Zemansky M. Fluvoxamine in the treatment of tricyclic-resistant depression. Psychiatr J Univ Ott. Sep. 1990;15(3):156-8. [pmid: 2123039].
1336 White PF, Rawal S, Recart A, Thornton L, Litle M, Stool L. Can the bispectral index be used to predict seizure time and awakening after electroconvulsive therapy. Anesth Analg. Jun. 2003;96(6):1636-9. table of contents. [pmid: 12760987].
1337 Whittal ML, Woody SR, McLean PD, Rachman SJ, Robichaud M. Treatment of obsessions: a randomized controlled trial. Behav Res Ther. Apr. 2010;48(4):295-303. [pmid: 19969286].
1338 Whyte EM, Basinski J, Farhi P, Dew MA, Begley A, Mulsant BH, et al. Geriatric depression treatment in nonresponders to selective serotonin reuptake inhibitors. J Clin Psychiatry. Dec. 2004;65(12):1634-41. [pmid: 15641868].
1339 Widepalm K. Comparison of fronto-frontal and temporo-parietal unilateral non-dominant ECT. A retrograde memory study. Acta Psychiatr Scand. Apr. 1987;75(4):441-4. [pmid: 3591425].
1340 Wijeratne C, Sachdev P. Treatment-resistant depression: critique of current approaches. Aust N Z J Psychiatry. Sep. 2008;42(9):751-62. [pmid: 18696279].
1341 Wijkstra J, Nolen WA, Algra A, van Vliet IM, Kahn RS. Relapse prevention in major depressive disorder after successful ECT: a literature review and a naturalistic case series. Acta Psychiatr Scand. Dec. 2000;102(6):454-60. [pmid: 11142436].
1342 Wilhelm K, Mitchell P, Boyce P, Hickie I, Brodaty H, Austin MP, et al. Treatment resistant depression in an Australian context. I: The utility of the term and approaches to management. Aust N Z J Psychiatry. Mar. 1994;28(1):14-22. [pmid: 7915106].
1343 Wilhelm K, Mitchell P, Sengoz A, Hickie I, Brodaty H, Boyce P. Treatment resistant depression in an Australian context. II: Outcome of a series of patients. Aust N Z J Psychiatry. Mar. 1994;28(1):23-33. [pmid: 7915107].
1344 Wilkinson AM, Anderson DN, Abou-Saleh MT, Wesson M, Blair JA, Farrar G, et al. 5-Methyltetrahydrofolate level in the serum of depressed subjects and its relationship to the outcome of ECT. J Affect Disord. Nov. 1994;32(3):163-8. [pmid: 7852658].
1345 Wilkinson P, Hawton K, Andrew B, Fagg J. Does the duration of illness before treatment affect the time taken to recover on treatment in severely depressed women?. J Affect Disord. Nov. 25. 1996;41(2):89-92. [pmid: 8961035].
1346 Williams GO. Management of depression in the elderly. Prim Care. Jun. 1989;16(2):451-74. [pmid: 2664841].
1347 Williams JH, O'Brien JT, Cullum S. Time course of response to electroconvulsive therapy in elderly depressed subjects. Int J Geriatr Psychiatry. May. 1997;12(5):563-6. [pmid: 9193966].
1348 Williams MD, Rummans T, Sampson S, Knapp R, Mueller M, Husain MM, et al. Outcome of electroconvulsive therapy by race in the Consortium for Research on Electroconvulsive Therapy multisite study. J Ect. Jun. 2008;24(2):117-21. [pmid: 18580553].
1349 Winokur G, Coryell W, Keller M, Scheftner WA. Relationship of electroconvulsive therapy to course in affective illness: a collaborative study. Eur Arch Psychiatry Clin Neurosci. 1990;240(1):54-9. [pmid: 2147905].
1350 Woggon B. Methodology of measuring the efficacy of antidepressants--European viewpoint. Psychopharmacology (Berl). Suppl. 1992;106:S90-2. [pmid: 1546151].
1351 Wolkowitz OM, Reus VI, Roberts E, Manfredi F, Chan T, Raum WJ, et al. Dehydroepiandrosterone (DHEA) treatment of depression. Biol Psychiatry. Feb. 1. 1997;41(3):311-8. [pmid: 9024954].
1352 Yatham LN, Zis AP, Lam RW, Srisurapanont M, McGarvey K, Agbayewa O. Role of serotonin3 receptors in prolactin release induced by electroconvulsive therapy: a study with ondansetron. Psychiatry Res. Feb. 28. 1996;60(1):33-9. [pmid: 8852866].
1353 Yildiz A, Mantar A, Simsek S, Onur E, Gokmen N, Fidaner H. Combination of pharmacotherapy with electroconvulsive therapy in prevention of depressive relapse: a pilot controlled trial. J ECT. Jun. 2010;26(2):104-10. [pmid: 19935091].
1354 Yip AG, Carpenter LL. Transcranial magnetic stimulation for medication-resistant depression. J Clin Psychiatry. Apr. 2010;71(4):502-3. [pmid: 20409447].
1355 Yoshimura R, Hori H, Ikenouchi-Sugita A, Umene-Nakano W, Ueda N, Nakamura J. Higher plasma interleukin-6 (IL-6) level is associated with SSRI- or SNRI-refractory depression. Prog Neuropsychopharmacol Biol Psychiatry. Jun. 15. 2009;33(4):722-6. [pmid: 19332097].
1356 Yoshimura R, Ikenouchi-Sugita A, Hori H, Umene-Nakano W, Katsuki A, Hayashi K, et al. Adding a low dose atypical antipsychotic drug to an antidepressant induced a rapid increase of plasma brain-derived neurotrophic factor levels in patients with treatment-resistant depression. Prog Neuropsychopharmacol Biol Psychiatry. Mar. 17. 2010;34(2):308-12. [pmid: 20005280].
1357 Yoshimura R, Umene-Nakano W, Ueda N, Ikenouchi-Sugita A, Hori H, Nakamura J. Addition of risperidone to sertraline improves sertraline-resistant refractory depression without influencing plasma concentrations of sertraline and desmethylsertraline. Hum Psychopharmacol. Dec. 2008;23(8):707-13. [pmid: 18803170].
1358 Young SN. Use of tryptophan in combination with other antidepressant treatments: a review. J Psychiatry Neurosci. Dec. 1991;16(5):241-6. [pmid: 1797098].
1359 Yu ZJ, Weller RA, Sandidge K, Weller EB. Vagus nerve stimulation: can it be used in adolescents or children with treatment-resistant depression?. Curr Psychiatry Rep. Apr. 2008;10(2):116-22. [pmid: 18474201].
1360 Yukimasa T, Yoshimura R, Tamagawa A, Uozumi T, Shinkai K, Ueda N, et al. High-frequency repetitive transcranial magnetic stimulation improves refractory depression by influencing catecholamine and brain-derived neurotrophic factors. Pharmacopsychiatry. Mar. 2006;39(2):52-9. [pmid: 16555165].
1361 Yuuki N, Ida I, Oshima A, Kumano H, Takahashi K, Fukuda M, et al. HPA axis normalization, estimated by DEX/CRH test, but less alteration on cerebral glucose metabolism in depressed patients receiving ECT after medication treatment failures. Acta Psychiatr Scand. Oct. 2005;112(4):257-65. [pmid: 16156832].
1362 Zajecka JM, Jeffries H, Fawcett J. The efficacy of fluoxetine combined with a heterocyclic antidepressant in treatment-resistant depression: a retrospective analysis. J Clin Psychiatry. Aug. 1995;56(8):338-43. [pmid: 7635848].
1363 Zanardi R, Magri L, Rossini D, Malaguti A, Giordani S, Lorenzi C, et al. Role of serotonergic gene polymorphisms on response to transcranial magnetic stimulation in depression. Eur Neuropsychopharmacol. Oct. 2007;17(10):651-7. [pmid: 17466494].
1364 Zanardini R, Gazzoli A, Ventriglia M, Perez J, Bignotti S, Rossini PM, et al. Effect of repetitive transcranial magnetic stimulation on serum brain derived neurotrophic factor in drug resistant depressed patients. J Affect Disord. Mar. 2006;91(1):83-6. [pmid: 16448701].
1365 Zapletalek M, Zbytovsky J, Kudrnova K. Clinical experience with maprotilin and maprotilin/clomipramine infusions in resistant depression. Act Nerv Super (Praha). May. 1982;24(2):73-6. [pmid: 7102227].
1366 Zeman M, Jirak R, Jachymova M, Vecka M, Tvrzicka E, Zak A. Leptin, adiponectin, leptin to adiponectin ratio and insulin resistance in depressive women. Neuro Endocrinol Lett. 2009;30(3):387-95. [pmid: 19855365].
1367 Zervas IM, Pehlivanidis AA, Papakostas YG, Markianos M, Papadimitriou GN, Stefanis CN. Effects of TRH administration on orientation time and recall after ECT. J Ect. Dec. 1998;14(4):236-40. [pmid: 9871843].
1368 Zetin M, Hoepner CT, Bjornson L. Rational antidepressant selection: applying evidence-based medicine to complex real-world patients. Psychopharmacol Bull. 2006;39(1):38-104. [pmid: 17065974].
1369 Zhang X, Liu K, Sun J, Zheng Z. Safety and feasibility of repetitive transcranial magnetic stimulation (rTMS) as a treatment for major depression during pregnancy. Arch Womens Ment Health. Aug. 2010;13(4):369-70. [pmid: 20386939].
1370 Zielinski RJ, Roose SP, Devanand DP, Woodring S, Sackeim HA. Cardiovascular complications of ECT in depressed patients with cardiac disease. Am J Psychiatry. Jun. 1993;150(6):904-9. [pmid: 8494067].
1371 Zimmer B, Rosen J, Thornton JE, Perel JM, Reynolds CF 3rd. Adjunctive lithium carbonate in nortriptyline-resistant elderly depressed patients. J Clin Psychopharmacol. Aug. 1991;11(4):254-6. [pmid: 1918424].
1372 Zimmerman M, Coryell W, Pfohl B, Corenthal C, Stangl D. ECT response in depressed patients with and without a DSM-III personality disorder. Am J Psychiatry. Aug. 1986;143(8):1030-2. [pmid: 3728718].
1373 Zimmerman M, Pfohl B, Coryell W, Stangl D. The prognostic validity of DSM-III axis IV in depressed inpatients. Am J Psychiatry. Jan. 1987;144(1):102-6. [pmid: 3799826].
1374 Zis AP, Yatham LN, Lam RW, Clark CM, Srisurapanont M, McGarvey K. Effect of stimulus intensity on prolactin and cortisol release induced by unilateral electroconvulsive therapy. Neuropsychopharmacology. Sep. 1996;15(3):263-70. [pmid: 8873109].
1375 Zisook S, Rush AJ, Haight BR, Clines DC, Rockett CB. Use of bupropion in combination with serotonin reuptake inhibitors. Biol Psychiatry. Feb. 1. 2006;59(3):203-10. [pmid: 16165100].
1376 Zitman FG, Linssen AC, Edelbroek PM, Stijnen T. Low dose amitriptyline in chronic pain: the gain is modest. Pain. Jul. 1990;42(1):35-42. [pmid: 2234996].
1377 Zobel A, Joe A, Freymann N, Clusmann H, Schramm J, Reinhardt M, et al. Changes in regional cerebral blood flow by therapeutic vagus nerve stimulation in depression: an exploratory approach. Psychiatry Res. Aug. 30. 2005;139(3):165-79. [pmid: 16043331].
1378 Zoger S, Svedlund J, Holgers KM. The effects of sertraline on severe tinnitus suffering--a randomized, double-blind, placebo-controlled study. J Clin Psychopharmacol. Feb. 2006;26(1):32-9. [pmid: 16415703].
1379 Zohar J, Insel TR. Drug treatment of obsessive-compulsive disorder. J Affect Disord. Sep-Oct. 1987;13(2):193-202. [pmid: 2960711].
1380 Zornberg GL, Pope HG Jr. Treatment of depression in bipolar disorder: new directions for research. J Clin Psychopharmacol. Dec. 1993;13(6):397-408. [pmid: 8120153].
1381 Zorumski CF, Rutherford JL, Burke WJ, Reich T. ECT in primary and secondary depression. J Clin Psychiatry. Jun. 1986;47(6):298-300. [pmid: 3711027].
1382 Zubenko GS, Mulsant BH, Rifai AH, Sweet RA, Pasternak RE, Marino LJ Jr, et al. Impact of acute psychiatric inpatient treatment on major depression in late life and prediction of response. Am J Psychiatry. Jul. 1994;151(7):987-94. [pmid: 8010384].
1383 Zullino D, Baumann P. Lithium augmentation in depressive patients not responding to selective serotonin reuptake inhibitors. Pharmacopsychiatry. Jul. 2001;34(4):119-27. [pmid: 11518471].
1384 Zusky PM, Biederman J, Rosenbaum JF, Manschreck TC, Gross CC, Weilberg JB, et al. Adjunct low dose lithium carbonate in treatment-resistant depression: a placebo-controlled study. J Clin Psychopharmacol. Apr. 1988;8(2):120-4. [pmid: 3131389].

## Handsearch Results = 310 articles (excluding duplicates)

1 Aarre TF, Dahl AA, Johansen JB, Kjonniksen I, Neckelmann D. Efficacy of repetitive transcranial magnetic stimulation in depression: a review of the evidence. Nord J Psychiatry. 2003;57(3):227-32. [pmid: 12775299].
2 Abrams R, DeVito RA. Clinical efficacy of unilateral ECT. Diseases of the nervous system. 1969;30(4):262-3. [pmid: 4890011].
3 American Psychiatric Association. Committee on Electroconvulsive T, Weiner RD. The practice of electroconvulsive therapy : a task force report of the american Psychiatric Association. Washington, D.C. American Psychiatric Assoication.
4 Anttila S, Huuhka K, Huuhka M, Illi A, Rontu R, Leinonen E, et al. Catechol-O-methyltransferase (COMT) polymorphisms predict treatment response in electroconvulsive therapy. Pharmacogenomics J. Apr. 2008;8(2):113-6. [pmid: 17700596].
5 Artigas F, Perez V, Alvarez E. Pindolol induces a rapid improvement of depressed patients treated with serotonin reuptake inhibitors. Arch Gen Psychiatry. Mar. 1994;51(3):248-51. [pmid: 8122960].
6 Avery D. Transcranial magnetic stimulation in the treatment of depression. Essent Psychopharmacol. 2001;4:37-48.
7 Avery D, Winokur G. Mortality in depressed patients treated with electroconvulsive therapy and antidepressants. Archives of General Psychiatry. 1976;33(9):1029-37. [pmid: 962487].
8 Azuma H, Fujita A, Otsuki K, Nakano Y, Kamao T, Nakamura C, et al. Ictal electroencephalographic correlates of posttreatment neuropsychological changes in electroconvulsive therapy: a hypothesis-generation study. J Ect. Sep. 2007;23(3):163-8. [pmid: 17804990].
9 Bagadia VN, Shah LP, Pradhan PV. Evaluation of cognitive effects of ECT (preliminary observations). Indian J Psychiatry. 1981;23(4):324-9. [pmid: 22058556].
10 Bagby RM, Quilty LC, Segal ZV, McBride CC, Kennedy SH, Costa PT. Personality and differential treatment response in major depression: a randomized controlled trial comparing cognitive-behavioural therapy and pharmacotherapy. Can J Psychiatry. Jun. 2008;53(6):361-70. [pmid: 18616856].
11 Baghai TC, Marcuse A, Moller HJ, Rupprecht R. Electroconvulsive therapy at the Department of Psychiatry and Psychotherapy, University of Munich. Development during the years 1995-2002. Nervenarzt. May. 2005;76(5):597-612. [pmid: 15448918].
12 Bajbouj M, Lang UE, Neu P, Heuser I. Therapeutic brain stimulation and cortical excitability in depressed patients. Am J Psychiatry. Nov. 2005;162(11):2192-3. [pmid: 16263869].
13 Baldomero EB, Ubago JG, Cercos CL, Ruiloba JV, Calvo CG, Lopez RP. Venlafaxine extended release versus conventional antidepressants in the remission of depressive disorders after previous antidepressant failure: ARGOS study. Depress Anxiety. Aug. 10. 2005;22(2):68-76. [pmid: 16094658].
14 Barbee JG, Jamhour NJ. Lamotrigine as an augmentation agent in treatment-resistant depression. Journal of Clinical Psychiatry. 2002;63(8):737-41. [pmid: 12197456].
15 Barker AT, Jalinous R, Freeston H, Jarratt JA. Motor responses to noninvasive brain stimulation in clinical practice. Electroencephalogr Clin Neurophysiol. 1985;61:570-4.
16 Barker AT, Jalinous R, Freeston IL. Non-invasive magnetic stimulation of human motor cortex. Lancet. 1985;1(8437):1106-7. [pmid: 2860322].
17 Barton JL, Mehta S, Snaith RP. The prophylactic value of extra ECT in depressive illness. Acta Psychiatrica Scandinavica. 1973;49(4):386-92. [pmid: 4746007].
18 Bauer M, Hellweg R, Graf KJ, Baumgartner A. Treatment of refractory depression with high-dose thyroxine. Neuropsychopharmacology. Jun. 1998;18(6):444-55. [pmid: 9571653].
19 Baxter LR Jr, Schwartz JM, Phelps ME, Mazziotta JC, Guze BH, Selin CE, et al. Reduction of prefrontal cortex glucose metabolism common to three types of depression. Archives of General Psychiatry. 1989;46(3):243-50. [pmid: 2784046].
20 Beale MD, Kellner CH, Pritchett JT, Bernstein HJ, Burns CM, Knapp R. Stimulus dose-titration in ECT: A 2-year clinical experience. Convulsive Therapy. 1994;10(2):171-6. [pmid: 8069643].
21 Bech P. Meta-analysis of placebo-controlled trials with mirtazapine using the core items of the Hamilton Depression Scale as evidence of a pure antidepressive effect in the short-term treatment of major depression. International Journal of Neuropsychopharmacology. 2001;4(4):337-45. [pmid: 11806859].
22 Belmaker RH, Fleischmann A. Transcranial magnetic stimulation: a potential new frontier in psychiatry. Biological Psychiatry. 1995;38(7):419-21. [pmid: 8672601].
23 Ben-Menachem E. Vagus nerve stimulation, side effects, and long-term safety. Journal of Clinical Neurophysiology. 2001;18(5):415-8. [pmid: 11709646].
24 Ben-Shachar D, Belmaker RH, Grisaru N, Klein E. Transcranial magnetic stimulation induces alterations in brain monoamines. Journal of Neural Transmission. 1997;104(2-3):191-7. [pmid: 9203081].
25 Bergstrom RF, Peyton AL, Lemberger L. Quantification and mechanism of the fluoxetine and tricyclic antidepressant interaction. Clin Pharmacol Ther. Mar. 1992;51(3):239-48. [pmid: 1544284].
26 Berman RM, Marcus RN, Swanink R, et al. The efficacy and safety of aripiprazole as adjunctive therapy in major depressive disorder : A multicenter, randomized, double-blind, placebo-controlled study. Memphis, TN. ETATS-UNIS: Physicians Postgraduate Press. 2007:11.
27 Berman RM, Darnell AM, Miller HL, Anand A, Charney DS. Effect of pindolol in hastening response to fluoxetine in the treatment of major depression: a double-blind, placebo-controlled trial. Am J Psychiatry. Jan. 1997;154(1):37-43. [pmid: 8988956].
28 Berman RM, Fava M, Thase ME, Trivedi MH, Swanink R, McQuade RD, et al. Aripiprazole augmentation in major depressive disorder: a double-blind, placebo-controlled study in patients with inadequate response to antidepressants. CNS Spectr. 2009/05/02. 2009:197-206.
29 Bidder TG, Strain JJ, Brunschwig L. Bilateral and unilateral ECT: follow-up study and critique. American Journal of Psychiatry. 1970;127(6):737-45. [pmid: 5482867].
30 Black DW, Winokur G, Mohandoss E, Woolson RF, Nasrallah A. Does treatment influence mortality in depressives? A follow-up of 1076 patients with major affective disorders. Annals of Clinical Psychiatry. 1989;1(3):165-73.
31 Blackburn IM, Moore RG. Controlled acute and follow-up trial of cognitive therapy and pharmacotherapy in out-patients with recurrent depression. Br J Psychiatry. Oct. 1997;171:328-34. [pmid: 9373420].
32 Bonne O, Krausz Y, Shapira B, Bocher M, Karger H, Gorfine M, et al. Increased cerebral blood flow in depressed patients responding to electroconvulsive therapy. Journal of Nuclear Medicine. 1996;37(7):1075-80. [pmid: 8965172].
33 Boroojerdi B, Prager A, Muellbacher W, Cohen LG. Reduction of human visual cortex excitability using 1-Hz transcranial magnetic stimulation. Neurology. 2000;54(7):1529-31. [pmid: 10751273].
34 Bouwer C, Stein DJ. Buspirone is an effective augmenting agent of serotonin selective re-uptake inhibitors in severe treatment-refractory depression. S Afr Med J. 4. 1997;87(4 Suppl):534-7. 40. [pmid: 9180827].
35 Bratfos O, Haug JO. Electroconvulsive therapy and antidepressant drugs in manic-depressive disease. Treatment results at discharge and 3 months later. Acta Psychiatrica Scandinavica. 1965;41(4):588-96. [pmid: 5884008].
36 Brown WA, Harrison W. Are patients who are intolerant to one serotonin selective reuptake inhibitor intolerant to another?. J Clin Psychiatry. Jan. 1995;56(1):30-4. [pmid: 7836337].
37 Browne M, Lapierre YD, Hrdina PD, Horn E. Lithium as an adjunct in the treatment of major depression. Int Clin Psychopharmacol. Apr. 1990;5(2):103-10. [pmid: 2116474].
38 Bruce EM, Crone N, Fitzpatrick G, Frewin SJ, Gillis A, Lascelles CF, et al. A comparative trial of ECT and tofranil. American Journal of Psychiatry. 1960;117:76. [pmid: 13805124].
39 Burrows GD, Norman TR, Judd FK. Definition and differential diagnosis of treatment-resistant depression. International Clinical Psychopharmacology. 1994;9(SUPPL. 2):5-10. [pmid: 7930496].
40 Burt T, Lisanby SH, Sackeim HA. Neuropsychiatric applications of transcranial magnetic stimulation: A meta-analysis. International Journal of Neuropsychopharmacology. 2002;5(1):73-103. [pmid: 12057034].
41 Calabrese JR, Londborg PD, Shelton MD, Thase ME. Citalopram treatment of fluoxetine-intolerant depressed patients. J Clin Psychiatry. May. 2003;64(5):562-7. [pmid: 12755660].
42 Caliyurt O, Vardar E, Tuglu C, Abay E. Effects of propofol on electroconvulsive therapy seizure duration. Can J Psychiatry. Oct. 2004;49(10):707-8. [pmid: 15560320].
43 Calloway SP, Dolan RJ, Jacoby RJ, Levy R. ECT and cerebral atrophy. A computed tomographic study. Acta Psychiatrica Scandinavica. 1981;64(5):442-5. [pmid: 7347109].
44 Carney MW, Rogan PA, Sebastian J, Sheffield B. A controlled comparative trial of unilateral and bilateral sinusoidal and pulse E.C.T. in endogenous depression. Physicians' Drug Manual. 1976;7:9-128/1.
45 Carpenter LL, Yasmin S, Price LH. A double-blind, placebo-controlled study of antidepressant augmentation with mirtazapine. Biol Psychiatry. Jan. 15. 2002;51(2):183-8. [pmid: 11822997].
46 Cavanagh J, Smyth R, Goodwin GM. Relapse into mania or depression following lithium discontinuation: a 7-year follow-up. Acta Psychiatr Scand. Feb. 2004;109(2):91-5. [pmid: 14725588].
47 Chae JH, Nahas Z, Lomarev M, Denslow S, Lorberbaum JP, Bohning DE, et al. A review of functional neuroimaging studies of vagus nerve stimulation (VNS). Journal of Psychiatric Research. 2003;37(6):443-55. [pmid: 14563375].
48 Chen R, Classen J, Gerloff C, Celnik P, Wassermann EM, Hallett M, et al. Depression of motor cortex excitability by low-frequency transcranial magnetic stimulation. Neurology. 1997;48(5):1398-403. [pmid: 9153480].
49 Chouinard PA, Van Der Werf YD, Leonard G, Paus T. Modulating neural networks with transcranial magnetic stimulation applied over the dorsal premotor and primary motor cortices. Journal of Neurophysiology. 2003;90(2):1071-83. [pmid: 12702714].
50 Christiansen PE, Behnke K, Black CH, Ohrström JK, Bork-Rasmussen H, Nilsson J. Paroxetine and amitriptyline in the treatment of depression in general practice. Acta Psychiatrica Scandinavica. 1996;93(3):158-63. [pmid: 8739658].
51 Ciapparelli A, Dell'Osso L, Tundo A, Pini S, Chiavacci MC, Di Sacco I, et al. Electroconvulsive therapy in medication-nonresponsive patients with mixed mania and bipolar depression. J Clin Psychiatry. Jul. 2001;62(7):552-5. [pmid: 11488367].
52 Clayton AH, Warnock JK, Kornstein SG, Pinkerton R, Sheldon-Keller A, McGarvey EL. A placebo-controlled trial of bupropion SR as an antidote for selective serotonin reuptake inhibitor-induced sexual dysfunction. J Clin Psychiatry. Jan. 2004;65(1):62-7. [pmid: 14744170].
53 Coffey CE, Lucke J, Weiner RD, Krystal AD, Aque M. Seizure threshold in electroconvulsive therapy (ECT) II. The anticonvulsant effect of ECT. Biological Psychiatry. 1995;37(11):777-88. [pmid: 7647162].
54 Cole MG, Elie LM, McCusker J, Bellavance F, Mansour A. Feasibility and effectiveness of treatments for post-stroke depression in elderly inpatients: systematic review. J Geriatr Psychiatry Neurol. Spring. 2001;14(1):37-41. [pmid: 11281315].
55 Cooper-Kazaz R, Lerer B. Efficacy and safety of triiodothyronine supplementation in patients with major depressive disorder treated with specific serotonin reuptake inhibitors. Int J Neuropsychopharmacol. Aug. 2008;11(5):685-99. [pmid: 18047754].
56 Coppen A, Bailey J. Enhancement of the antidepressant action of fluoxetine by folic acid: a randomised, placebo controlled trial. J Affect Disord. Nov. 2000;60(2):121-30. [pmid: 10967371].
57 Correll GE, Futter GE. Two case studies of patients with major depressive disorder given low-dose (subanesthetic) ketamine infusions. Pain Med. Jan-Feb. 2006;7(1):92-5. [pmid: 16533209].
58 Costello CG, Belton GP, Abra JC, Dunn BE. The amnesic and therapeutic effects of bilateral and unilateral ECT. British Journal of Psychiatry. 1970;116(530):69-78. [pmid: 5411010].
59 Cummings JL. Frontal-subcortical circuits and human behavior. Archives of Neurology. 1993;50(8):873-80. [pmid: 8352676].
60 Dannon PN, Schreiber S, Dolberg OT, Shemer L, Grunhaus L. Transcranial magnetic stimulation is effective in the treatment of relapse of depression. International Journal of Psychiatry in Clinical Practice. 2000;4(3):223-6.
61 Datka W, Siwek M, Dudek D, Maczka G, Zieba A. [Working memory disturbances in patients with major depression after ECT treatment]. Psychiatr Pol. May-Jun. 2007;41(3):339-49. [pmid: 17900050].
62 Davidson J, McLeod M, Law-Yone B. A comparison of electroconvulsive therapy and combined phenelzine-amitriptyline in refractory depression. Archives of General Psychiatry. 1978;35(5):639-42. [pmid: 727903].
63 DeBattista C, Lembke A, Solvason HB, Ghebremichael R, Poirier J. A prospective trial of modafinil as an adjunctive treatment of major depression. J Clin Psychopharmacol. Feb. 2004;24(1):87-90. [pmid: 14709953].
64 DeBerry S. The effects of mediation-relaxation on anxiety and depression in a geriatric population. Psychotherapy. 1982;19(4):512-21.
65 D'Elia G. Comparison of electroconvulsive therapy with unilateral and bilateral stimulation, II: Therapeutic efficacy in endogenous depression. Acta Psychiatr Scand. 1970;215:30-43.
66 D'Elia G. Comparison of electroconvulsive therapy with unilateral and bilateral stimulation, III: Anterograde amnesia. Acta Psychiatr Scand Suppl. 1970;212:44-60. [pmid: 4917971].
67 Demitrack MA, Loo CK, Maixner DF, Avery D, Isenberg K, Dowd SM, et al. Transcranial Magnetic Stimuatlin (TMS) in the Treatment of Pharmacoresistant Major Depression: Examination of Cognitive Function During Acute Treatment. Society for Biological Psychiatry Annual Meeting and New Research Sessions of the American Psychiatric Association Annual Meeting. Vancouver, B.C. and San Francisco, CA. 2009.
68 Demitrack MA, Thase ME. Clinical significance of transcranial magnetic stimulation (TMS) in the treatment of pharmacoresistant depression: synthesis of recent data. Psychopharmacol Bull. 2009/07/25. 2009:5-38.
69 Demyttenaere K, Jaspers L. Review: Bupropion and SSRI-induced side effects. J Psychopharmacol. Sep. 2008;22(7):792-804. [pmid: 18308785].
70 DeRubeis RJ, Feeley M. Determinants of change in cognitive therapy for depression. Cognitive Therapy and Research. 1990;14(5):469-82.
71 DeRubeis RJ, Gelfand LA, Tang TZ, Simons AD. Medications versus cognitive behavior therapy for severely depressed outpatients: Mega-analysis of four randomized comparisons. American Journal of Psychiatry. 1999;156(7):1007-13. [pmid: 10401443].
72 Dietzfelbinger T, Möller HJ, Steinmeyer EM. Elektrokrampftherapie als ultima ratio bei antidepressiva-nonrespondern. Therapieresistenz unter Antidepressiva-Behandlung Tropon-Symposium V. 1990:167-85.
73 Dimitriou EC, Dimitriou CE. Buspirone augmentation of antidepressant therapy. J Clin Psychopharmacol. Dec. 1998;18(6):465-9. [pmid: 9864079].
74 Dording CM, Mischoulon D, Petersen TJ, Kornbluh R, Gordon J, Nierenberg AA, et al. The pharmacologic management of SSRI-induced side effects: a survey of psychiatrists. Ann Clin Psychiatry. Sep. 2002;14(3):143-7. [pmid: 12585563].
75 Dorr AE, Debonnel G. Effect of vagus nerve stimulation on serotonergic and noradrenergic transmission. Journal of Pharmacology and Experimental Therapeutics. 2006;318(2):890-8. [pmid: 16690723].
76 Drevets WC, Videen TO, Price JL, Preskorn SH, Carmichael ST, Raichle ME. A functional anatomical study of unipolar depression. Journal of Neuroscience. 1992;12(9):3628-41. [pmid: 1527602].
77 Duffett R, Lelliott P. Auditing electroconvulsive therapy. The third cycle. British Journal of Psychiatry. 1998;172(MAY):401-5. [pmid: 9747401].
78 Dunner DL, Russell JM. A long-term, naturalistic study of usual standard-of-care treatment in patients with treatment resistant depression. Proceedings of the ACNP Annual Meeting. San Juan, Puerto Rico. December 2003. 2003:150.
79 Ekers D, Richards D, Gilbody S. A meta-analysis of randomized trials of behavioural treatment of depression. Psychol Med. May. 2008;38(5):611-23. [pmid: 17903337].
80 Evans MD, Hollon SD, DeRubeis RJ, Piasecki JM, Grove WM, Garvey MJ, et al. Differential relapse following cognitive therapy and pharmacotherapy for depression. Archives of General Psychiatry. 1992;49(10):802-8. [pmid: 1417433].
81 Fabre I, Galinowski A, Oppenheim C, Gallarda T, Meder JF, de Montigny C, et al. Antidepressant efficacy and cognitive effects of repetitive transcranial magnetic stimulation in vascular depression: An open trial. International Journal of Geriatric Psychiatry. 2004;19(9):833-42. [pmid: 15352140].
82 Fagiolini A, Kupfer DJ. Is treatment-resistant depression a unique subtype of depression? Biol Psychiatry. Apr. 15. 2003;53(8):640-8.
83 Fahy S, Lawlor BA. Discontinuation of lithium augmentation in an elderly cohort. Int J Geriatr Psychiatry. Oct. 2001;16(10):1004-9. [pmid: 11607947].
84 Fatemi SH, Emamian ES, Kist DA. Venlafaxine and bupropion combination therapy in a case of treatment-resistant depression. Ann Pharmacother. Jun. 1999;33(6):701-3. [pmid: 10410184].
85 Fava GA, Rafanelli C, Silvana G, Canestrari R, Morphy MA. Six-year outcome for cognitive behavioral treatment of residual symptoms in major depression. American Journal of Psychiatry. 1998;155(10):1443-5. [pmid: 9766780].
86 Fava M. The combination of buspirone and bupropion in the treatment of depression. Psychother Psychosom. 2007;76(5):311-2. [pmid: 17700052].
87 Fava M, Alpert J, Nierenberg AA, Mischoulon D, Otto MW, Zajecka J, et al. A Double-blind, randomized trial of St John's wort, fluoxetine, and placebo in major depressive disorder. J Clin Psychopharmacol. Oct. 2005;25(5):441-7. [pmid: 16160619].
88 Fava M, McGrath PJ, Sheu WP. Switching to reboxetine: an efficacy and safety study in patients with major depressive disorder unresponsive to fluoxetine. J Clin Psychopharmacol. Aug. 2003;23(4):365-9. [pmid: 12920412].
89 Fava M, Thase ME, DeBattista C. A multicenter, placebo-controlled study of modafinil augmentation in partial responders to selective serotonin reuptake inhibitors with persistent fatigue and sleepiness. J Clin Psychiatry. Jan. 2005;66(1):85-93. [pmid: 15669893].
90 Fawcett J, Kravitz HM, Zajecka JM, Schaff MR. CNS stimulant potentiation of monoamine oxidase inhibitors in treatment-refractory depression. J Clin Psychopharmacol. Apr. 1991;11(2):127-32. [pmid: 2056139].
91 Feinsod M, Kreinin B, Chistyakov A, Klein E. Preliminary evidence for a beneficial effect of low-frequency, repetitive transcranial magnetic stimulation in patients with major depression and schizophrenia. Depression and Anxiety. 1998;7(2):65-8. [pmid: 9614593].
92 Fenton L, Fasula M, Ostroff R, Sanacora G. Can cognitive behavioral therapy reduce relapse rates of depression after ECT? a preliminary study. J Ect. Sep. 2006;22(3):196-8. [pmid: 16957536].
93 Ferreri M, Lavergne F, Berlin I, Payan C, Puech AJ. Benefits from mianserin augmentation of fluoxetine in patients with major depression non-responders to fluoxetine alone. Acta Psychiatr Scand. Jan. 2001;103(1):66-72. [pmid: 11202131].
94 Fink M. Convulsive Therapy: Theory and Practice. New York. Raven. 1979.
95 Fink M. Who should get ECT?. The Clinical Science of Electroconvulsive Therapy. 1993:3-15.
96 Fink M. Electroshock: restoring the mind. New York. Oxford University Press. 1999.
97 Fink M. Electroconvulsive therapy in medication-resistant depression. Treatment-Resistant Mood Disorders. 2001:223-38.
98 Fitzgerald PB, Brown TL, Marston NA, Daskalakis ZJ, de Castella A, Bradshaw JL, et al. Motor cortical excitability and clinical response to rTMS in depression. J Affect Disord. Oct. 1. 2004;82(1):71-6. [pmid: 15465578].
99 Fleminger JJ, de Horne DJ, Nair NP, Nott PN. Differential effect of unilateral and bilateral ECT. American Journal of Psychiatry. 1970;127(4):430-6. [pmid: 4918113].
100 Floyd M, Scogin F, McKendree-Smith NL, Floyd DL, Rokke PD. Cognitive therapy for depression: a comparison of individual psychotherapy and bibliotherapy for depressed older adults. Behavior Modification. 2004;28(2):297-318. [pmid: 14997954].
101 Floyd MR. Cognitive therapy for depression: a comparison of individual psychotherapy and bibliotherapy for depressed older adults. Dissertation Abstracts International. 1999;58(9 -B):5081.
102 Folkerts H. The ictal electroencephalogram as a marker for the efficacy of electroconvulsive therapy. European Archives of Psychiatry and Clinical Neuroscience. 1996;246(3):155-64. [pmid: 8739401].
103 Frank E, Rucci P, Katon W, Barrett J, Williams JW Jr, Oxman T, et al. Correlates of remission in primary care patients treated for minor depression. General Hospital Psychiatry. 2002;24(1):12-9. [pmid: 11814529].
104 Fredman SJ, Fava M, Kienke AS, White CN, Nierenberg AA, Rosenbaum JF. Partial response, nonresponse, and relapse with selective serotonin reuptake inhibitors in major depression: a survey of current “nextstep” practices. J Clin Psychiatry. Jun. 2000;61(6):403-8. [pmid: 10901336].
105 Freeman CPL, Basson JV, Crighton A. Double-blind controlled trial of electroconvulsive therapy (E.C.T.) and simulated E.C.T. in depressive illness. Lancet. 1978;1(8067):738-40. [pmid: 76748].
106 Fromholt P, Christensen AL, Sand Stromgren L. The effects of unilateral and bilateral electroconvulsive therapy on memory. Acta Psychiatrica Scandinavica. 1973;49(4):466-78. [pmid: 4746012].
107 Gallagher DE, Thompson LW. Treatment of major depressive disorder in older adult outpatients with brief psychotherapies. Psychotherapy. 1982;19(4):482-90.
108 Gallagher-Thompson D, Steffen AM. Comparative effects of cognitive-behavioral and brief psychodynamic psychotherapies for depressed family caregivers. Journal of Consulting and Clinical Psychology. 1994;62(3):543-9. [pmid: 8063980].
109 Geddes J, Carney S, Cowen P, Goodwin G, Rogers R, Dearness K, et al. Efficacy and safety of electroconvulsive therapy in depressive disorders: a systematic review and meta-analysis. Lancet. Mar. 8. 2003;361(9360):799-808. [pmid: 12642045].
110 George MS, Belmaker RH. Transcranial magnetic stimulation in neuropsychiatry. Washington, DC. American Psychiatric Press. 2000.
111 George MS, Wassermann EM. Rapid-rate transcranial magnetic stimulation and ECT. Convulsive Therapy. 1994;10(4):251-4. discussion 5.
112 Gitlin MJ, Suri R, Altshuler L, Zuckerbrow-Miller J, Fairbanks L. Bupropion-sustained release as a treatment for SSRI-induced sexual side effects. J Sex Marital Ther. Mar-Apr. 2002;28(2):131-8. [pmid: 11894796].
113 Gloaguen V, Cottraux J, Cucherat M, Blackburn IM. A meta-analysis of the effects of cognitive therapy in depressed patients. J Affect Disord. Apr. 1998;49(1):59-72. [pmid: 9574861].
114 Goodwin FK, Prange AJ Jr, Post RM, Muscettola G, Lipton MA. Potentiation of antidepressant effects by L-triiodothyronine in tricyclic nonresponders. Am J Psychiatry. Jan. 1982;139(1):34-8. [pmid: 7055275].
115 Gormsen L, Ribe AR, Raun P, Rosenberg R, Videbech P, Vestergaard P, et al. Pain thresholds during and after treatment of severe depression with electroconvulsive therapy. Eur J Pain. Oct. 2004;8(5):487-93. [pmid: 15324780].
116 Greenblatt M, Grosser GH, Wechsler H. Differential response of hospitalized depressed patients to somatic therapy. Am J Psychiatry. 1964;120:935-43. [pmid: 14138843].
117 Gregory S, Shawcross CR, Gill D. The Nottingham ECT study. A double-blind comparison of bilateral, unilateral and simulated ECT in depressive illness. British Journal of Psychiatry. 1985:520-4.
118 Grisaru N, Yarovslavsky U, Abarbanel J, Lamberg T, Belmaker RH. Transcranial magnetic stimulation in depression and schizophrenia. European Neuropsychopharmacology. 1994;4(3):287-8.
119 Gross M, Nakamura L, Pascual-Leone A, Fregni F. Has repetitive transcranial magnetic stimulation (rTMS) treatment for depression improved? A systematic review and meta-analysis comparing the recent vs. the earlier rTMS studies. Acta Psychiatr Scand. Sep. 2007;116(3):165-73. [pmid: 17655557].
120 Grunhaus L, Dolberg O, Lustig M. Relapse and recurrence following a course of ECT: Reasons for concern and strategies for further investigation. Journal of Psychiatric Research. 1995;29(3):165-72. [pmid: 7473293].
121 Gupta S, Ghaly N, Dewan M. Augmenting fluoxetine with dextroamphetamine to treat refractory depression. Hosp Community Psychiatry. Mar. 1992;43(3):281-3. [pmid: 1555827].
122 Guzzetta F, Tondo L, Centorrino F, Baldessarini RJ. Lithium treatment reduces suicide risk in recurrent major depressive disorder. J Clin Psychiatry. Mar. 2007;68(3):380-3. [pmid: 17388706].
123 Halliday AM, Davison K, Browne MW, Kreeger LC. A comparison of the effects on depression and memory of bilateral E.C.T. and unilateral E.C.T. to the dominant and non-dominant hemispheres. British Journal of Psychiatry. 1968;114(513):997-1012. [pmid: 4879296].
124 Hannan N, Hamzah Z, Akinpeloye HO, Meagher D. Venlafaxine-mirtazapine combination in the treatment of persistent depressive illness. J Psychopharmacol. Mar. 2007;21(2):161-4. [pmid: 17329295].
125 Hansen PE, Ravnkilde B, Videbech P, Clemmensen K, Sturlason R, Reiner M, et al. Low-Frequency Repetitive Transcranial Magnetic Stimulation Inferior to Electroconvulsive Therapy in Treating Depression. J ECT. 2010/03/31. 2010.
126 Hanss R, Bauer M, Bein B, Goeder R, Buttgereit B, Schulz-Du Bois AC, et al. Bispectral index-controlled anaesthesia for electroconvulsive therapy. Eur J Anaesthesiol. Mar. 2006;23(3):202-7. [pmid: 16430791].
127 Heikman P, Tuunainen A, Sailas E, Kuoppasalmi K. Seizures induced by low-dose right unilateral and bifrontal electroconvulsive stimuli. J Ect. Dec. 2003;19(4):189-93. [pmid: 14657770].
128 Helmstaedter C, Hoppe C, Elger CE. Memory alterations during acute high-intensity vagus nerve stimulation. Epilepsy Research. 2001;47(1-2):37-42. [pmid: 11673019].
129 Henry TR, Votaw JR, Pennell PB, Epstein CM, Bakay RAE, Faber TL, et al. Acute blood flow changes and efficacy of vagus nerve stimulation in partial epilepsy. Neurology. 1999;52(6):1166-73. [pmid: 10214738].
130 Herrington RN, Bruce A, Johnstone EC, Lader MH. Comparative trial of L tryptophan and E.C.T. in severe depressive illness. Lancet. 1974;2(7883):731-4. [pmid: 4143007].
131 Heshe J, Röder E, Theilgaard A. Unilateral and bilateral ECT. A psychiatric and psychological study of therapeutic effect and side effects. Acta Psychiatrica Scandinavica, Supplement. 1978;(275):1-180.
132 Hestad KA, Tonseth S, Stoen CD, Ueland T, Aukrust P. Raised plasma levels of tumor necrosis factor alpha in patients with depression: normalization during electroconvulsive therapy. J Ect. 2003:183-8.
133 Hihn H, Baune BT, Michael N, Markowitsch H, Arolt V, Pfleiderer B. Memory performance in severely depressed patients treated by electroconvulsive therapy. J Ect. Sep. 2006;22(3):189-95. [pmid: 16957535].
134 Hoflich G, Kasper S, Hufnagel A, Ruhrmann S, Moller HJ. Application of transcranial magnetic stimulation in treatment of drug-resistant major depression - A report of two cases. Human Psychopharmacology. 1993;8(5):361-5.
135 Holtzheimer PE 3rd, Russo J, Avery DH. A meta-analysis of repetitive transcranial magnetic stimulation in the treatment of depression. Psychopharmacology bulletin. 2001;35(4):149-69. [pmid: 12397863].
136 Holtzheimer P, Russo J, Avery D. Erratum for “a meta-analysis of repetitive transcranial magnetic stimulation in the treatment of depression”. Psychopharmacol Bull. 2003;37:5.
137 Holtzheimer PE, Avery D, Schlaepfer TE. Antidepressant effects of repetitive transcranial magnetic stimulation [4]. British Journal of Psychiatry. 2004;184(JUNE):541-2. [pmid: 15172952].
138 Howland RH. Chronic depression. Hospital and Community Psychiatry. 1993;44(7):633-9. [pmid: 8354502].
139 Huang CC, Su TP, Shan IK, Chang K, Wei IH. An open trial of daily left prefrontal cortex repetitive transcranial magnetic stimulation for treating medication-resistant depression. Eur Psychiatry. Dec. 2004;19(8):523-4. [pmid: 15589718].
140 Hutchinson J, Smedberg D. Treatment of depression: A comparative study of ECT and six drugs. Br J Psychiatry. 1963;109:536-8. [pmid: 13955929].
141 Huuhka K, Anttila S, Huuhka M, Hietala J, Huhtala H, Mononen N, et al. Dopamine 2 receptor C957T and catechol-o-methyltransferase Val158Met polymorphisms are associated with treatment response in electroconvulsive therapy. Neurosci Lett. 2008:79-83.
142 Huuhka MJ, Seinela L, Reinikainen P, Leinonen EV. Cardiac arrhythmias induced by ECT in elderly psychiatric patients: experience with 48-hour Holter monitoring. J Ect. Mar. 2003;19(1):22-5. [pmid: 12621273].
143 Iosifescu DV, Bolo NR, Nierenberg AA, Jensen JE, Fava M, Renshaw PF. Brain bioenergetics and response to triiodothyronine augmentation in major depressive disorder. Biol Psychiatry. Jun. 15. 2008;63(12):1127-34. [pmid: 18206856].
144 Jacobsen FM. Possible augmentation of antidepressant response by buspirone. J Clin Psychiatry. May. 1991;52(5):217-20. [pmid: 2033029].
145 Janicak PG, Nahas Z, Lisanby SH, Solvason HB, Sampson S, McDonald W, et al. Durability of acute tesponse to TMS in the treatment of major depression: relapse during a continuation pharmacotherapy extension study. Society for Biological Psychiatry Annual Meeting. 2007 May. San Diego, CA. 2007.
146 Joffe RT, Levitt AJ, Sokolov STH, Young LT. Response to an open trial of a second SSRI in major depression. Journal of Clinical Psychiatry. 1996;57(3):114-5. [pmid: 8617695].
147 Judd LL, Akiskal HS, Schettler PJ, Coryell W, Endicott J, Maser JD, et al. A prospective investigation of the natural history of the long-term weekly symptomatic status of bipolar II disorder. Arch Gen Psychiatry. 2003:261-9.
148 Kaplan B, Chistyakov A, Kreinin I, Hafner H, Feinsod M, Klein E. The effect of electroconvulsive therapy and repetitive transcranial magnetic stimulation on cortical excitability in patients with major depression. Muscle & Nerve Supplement. 2003:12.
149 Kasper S, Heiden A. Do SSRIs differ in their antidepressant efficacy. Human Psychopharmacology. 1995;10(SUPPL. 3).
150 Keller MB, Gelenberg AJ, Hirschfeld RMA, Rush AJ, Thase ME, Kocsis JH, et al. The treatment of chronic depression, Part 2: A double-blind, randomized trial of sertraline and imipramine. Journal of Clinical Psychiatry. 1998;59(11):598-607. [pmid: 9862606].
151 Keller MB, Lavori PW, Mueller TI, Endicott J, Coryell W, Hirschfeld RMA, et al. Time to recovery, chronicity, and levels of psychopathology in major depression: A 5-year prospective follow-up of 431 subjects. Archives of General Psychiatry. 1992;49(10):809-16. [pmid: 1417434].
152 Keller MB, Lavori PW, Rice J. The persistent risk of chronicity in recurrent episodes of nonbipolar major depressive disorder: A prospective follow-up. Am J Psychiatry. 1992;1431:24-8.
153 Keller MB, McCullough JP, Klein DN, Arnow B, Dunner DL, Gelenberg AJ, et al. A comparison of nefazodone, the cognitive behavioral-analysis system of psychotherapy, and their combination for the treatment of chronic depression. New England Journal of Medicine. 2000;342(20):1462-70. [pmid: 10816183].
154 Kellner CH, Fink M, Knapp R, Petrides G, Husain M, Rummans T, et al. Relief of expressed suicidal intent by ECT: a consortium for research in ECT study. Am J Psychiatry. May. 2005;162(5):977-82. [pmid: 15863801].
155 Kennedy SH, McCann SM, Masellis M, McIntyre RS, Raskin J, McKay G, et al. Combining bupropion SR with venlafaxine, paroxetine, or fluoxetine: a preliminary report on pharmacokinetic, therapeutic, and sexual dysfunction effects. J Clin Psychiatry. Mar. 2002;63(3):181-6. [pmid: 11926715].
156 Kho KH, van Vreeswijk MF, Simpson S, Zwinderman AH. A meta-analysis of electroconvulsive therapy efficacy in depression. J Ect. Sep. 2003;19(3):139-47. [pmid: 12972983].
157 Klausner EJ, Clarkin JF, Spielman L, Pupo C, Abrams R, Alexopoulos GS. Late-life depression and functional disability: the role of goal-focused group psychotherapy. International Journal of Geriatric Psychiatry. 1998;13(10):707-16. [pmid: 9818307].
158 Kocsis JH, Friedman RA, Markowitz JC, Leon AC, Miller NL, Gniwesch L, et al. Maintenance therapy for chronic depression: A controlled clinical trial of desipramine. Archives of General Psychiatry. 1996;53(9):769-76. [pmid: 8792753].
159 Koran LM, Gelenberg AJ, Kornstein SG, Howland RH, Friedman RA, DeBattista C, et al. Sertraline versus imipramine to prevent relapse in chronic depression. Journal of Affective Disorders. 2001;65(1):27-36. [pmid: 11426506].
160 Kozel FA, George MS. Meta-analysis of left prefrontal repetitive transcranial magnetic stimulation (rTMS) to treat depression. J Psychiatr Pract. 2002;8(5):270-5. [pmid: 15985889].
161 Kraus RP. Rapid cycling triggered by pindolol augmentation of paroxetine, but not with desipramine. Depression. 1996;4(2):92-4. [pmid: 9160648].
162 Kroessler D. Relative efficacy rates for therapies of delusional depression. Convulsive Therapy. 1985;1(3):173-82. [pmid: 11940821].
163 Kuhs H. Degrees of treatment resistance in depressive disorders on the basis of somatotherapeutic trials. STUFEN IN DER BEHANDLUNGSRESISTENZ BEI DEPRESSIVEN STORUNGEN, DEFINIERT NACH SOMATOTHERAPEUTISCHEN VERFAHREN. 1995;66(7):561-7.
164 Kunugi H, Ida I, Owashi T, Kimura M, Inoue Y, Nakagawa S, et al. Assessment of the dexamethasone/CRH test as a state-dependent marker for hypothalamic-pituitary-adrenal (HPA) axis abnormalities in major depressive episode: a Multicenter Study. Neuropsychopharmacology. 2006:212-20.
165 Laidlaw K, Davidson K, Toner H, Jackson G, Clark S, Law J, et al. A randomised controlled trial of cognitive behaviour therapy vs treatment as usual in the treatment of mild to moderate late life depression. Int J Geriatr Psychiatry. Aug. 2008;23(8):843-50. [pmid: 18311844].
166 Lalitanatpong D. The use of electroconvulsive therapy and the length of stay of psychiatric inpatients at King Chulalongkorn Memorial Hospital, Thai Red Cross Society. J Med Assoc Thai. 2005:S142-8.
167 Lam RW, Chan P, Wilkins-Ho M, Yatham LN. Repetitive Transcranial Magnetic Stimulation for Treatment-Resistant Depression: A Systematic Review and Metaanalysis. Canadian journal of psychiatry Revue canadienne de psychiatrie. 2008;53(9):621. [pmid: 18801225].
168 Leichsenring F, Rabung S. Effectiveness of long-term psychodynamic psychotherapy: a meta-analysis. JAMA. 2008/10/02. 2008:1551-65.
169 Levitt AJ, Joffe RT, Kamil R, McIntyre R. Do depressed subjects who have failed both fluoxetine and a tricyclic antidepressant respond to the combination?. J Clin Psychiatry. Sep. 1999;60(9):613-6. [pmid: 10520980].
170 Levy R. The clinical evaluation of unilateral electroconvulsive therapy. British Journal of Psychiatry. 1968;114(509):459-63. [pmid: 5656265].
171 Licht RW, Qvitzau S. Treatment strategies in patients with major depression not responding to first-line sertraline treatment. A randomised study of extended duration of treatment, dose increase or mianserin augmentation. Psychopharmacology (Berl). May. 2002;161(2):143-51. [pmid: 11981594].
172 Lincoln NB, Flannaghan T. Cognitive behavioral psychotherapy for depression following stroke: A randomized controlled trial. Stroke. 2003;34(1):111-5. [pmid: 12511760].
173 Linet LS. Treatment of a refractory depression with a combination of fluoxetine and d-amphetamine. Am J Psychiatry. Jun. 1989;146(6):803-4. [pmid: 2786343].
174 Loo CK, Mitchell PB. A review of the efficacy of transcranial magnetic stimulation (TMS) treatment for depression, and current and future strategies to optimize efficacy. J Affect Disord. Nov. 2005;88(3):255-67. [pmid: 16139895].
175 Lyketsos CG, DelCampo L, Steinberg M, Miles Q, Steele CD, Munro C, et al. Treating depression in Alzheimer disease: efficacy and safety of sertraline therapy, and the benefits of depression reduction: the DIADS. Archives of General Psychiatry. 2003;60(7):737-46. [pmid: 12860778].
176 Maihofner C, Ropohl A, Reulbach U, Hiller M, Elstner S, Kornhuber J, et al. Effects of repetitive transcranial magnetic stimulation in depression: a magnetoencephalographic study. Neuroreport. Nov. 7. 2005;16(16):1839-42. [pmid: 16237338].
177 Malitz S, Sackeim H, Decina P. Low dosage ECT: Electrode placement and acute physiological and cognitive effects. Am J Psychiatry. 1984;4:47-53.
178 Mandel MR, Welch CA, Mieske M. Prediction of response to ECT in tricyclic-intolerant or tricyclic-resistant depressed patients. McLean Hosp J. 1977;4:203-9.
179 Manganotti P, Bortolomasi M, Zanette G, Pawelzik T, Giacopuzzi M, Fiaschi A. Intravenous clomipramine decreases excitability of human motor cortex. A study with paired magnetic stimulation. Journal of the Neurological Sciences. 2001;184(1):27-32. [pmid: 11231029].
180 Marangell LB, Suppes T, Zboyan HA, Prashad SJ, Fischer G, Snow D, et al. A 1-year pilot study of vagus nerve stimulation in treatment-resistant rapid-cycling bipolar disorder. J Clin Psychiatry. Feb. 2008;69(2):183-9. [pmid: 18211128].
181 McDonald IM, Perkins M, Marjerrison G, Podilsky M. A controlled comparison of amitriptyline and electroconvulsive therapy in the treatment of depression. American Journal of Psychiatry. 1966;122(12):1427-31. [pmid: 5326021].
182 Michelson D, Kociban K, Tamura R, Morrison MF. Mirtazapine, yohimbine or olanzapine augmentation therapy for serotonin reuptake-associated female sexual dysfunction: a randomized, placebo controlled trial. J Psychiatr Res. May-Jun. 2002;36(3):147-52. [pmid: 11886692].
183 Miller IW, Keitner GI, Schatzberg AF, Klein DN, Thase ME, Rush AJ, et al. The treatment of chronic depression, Part 3: Psychosocial functioning before and after treatment with sertraline or imipramine. Journal of Clinical Psychiatry. 1998;59(11):608-19. [pmid: 9862607].
184 Moustgaard G. Treatment-refractory depression successfully treated with the combination of mirtazapine and lithium. J Clin Psychopharmacol. 2000;268.
185 Mulrow CD, Williams JW Jr, Trivedi M, Chiquette E, Aguilar C, Cornell JE, et al. Treatment of depression--newer pharmacotherapies. Psychopharmacol Bull. 1998;34(4):409-795. [pmid: 10513454].
186 Nahas Z, Teneback C, Chae JH, Mu Q, Molnar C, Kozel FA, et al. Serial vagus nerve stimulation functional MRI in treatment-resistant depression. Neuropsychopharmacology. Aug. 2007;32(8):1649-60. [pmid: 17203016].
187 Naritoku DK, Terry WJ, Helfert RH. Regional induction of fos immunoreactivity in the brain by anticonvulsant stimulation of the vagus nerve. Epilepsy Research. 1995;22(1):53-62. [pmid: 8565967].
188 Nelson AL, Cohen JT, Greenberg D, Kent DM. Much cheaper, almost as good: decrementally cost-effective medical innovation. Ann Intern Med. 2009/11/04. 2009:662-7.
189 Nemeroff CB, Heim CM, Thase ME, Klein DN, Rush AJ, Schatzberg AF, et al. Differential responses to psychotherapy versus pharmacotherapy in patients with chronic forms of major depression and childhood trauma. Proc Natl Acad Sci U S A. 2003/11/15. 2003:14293-6.
190 Nemeroff CB, Mayberg HS, Krahl SE, McNamara J, Frazer A, Henry TR, et al. VNS therapy in treatment-resistant depression: Clinical evidence and putative neurobiological mechanisms. Neuropsychopharmacology. 2006;31(7):1345-55. [pmid: 16641939].
191 Nemets B, Mishory A, Levine J, Belmaker RH. Inositol addition does not improve depression in SSRI treatment failures. J Neural Transm. 1999;106(7-8):795-8. [pmid: 10907738].
192 Nemets B, Stahl Z, Belmaker RH. Addition of omega-3 fatty acid to maintenance medication treatment for recurrent unipolar depressive disorder. Am J Psychiatry. Mar. 2002;159(3):477-9. [pmid: 11870016].
193 Nestler EJ. Antidepressant treatments in the 21st century. Biological Psychiatry. 1998;44(7):526-33. [pmid: 9787876].
194 Nierenberg AA, Amsterdam JD. Treatment-resistant depression: Definition and treatment approaches. Journal of Clinical Psychiatry. 1990;51(6 SUPPL):39-47. [pmid: 2112132].
195 Nierenberg AA, Feighner JP, Rudolph R, Cole JO, Sullivan J. Venlafaxine for treatment-resistant unipolar depression. Journal of Clinical Psychopharmacology. 1994;14(6):419-23. [pmid: 7884023].
196 Nierenberg AA, Papakostas GI, Petersen T, Kelly KE, Iacoviello BM, Worthington JJ, et al. Nortriptyline for treatment-resistant depression. J Clin Psychiatry. Jan. 2003;64(1):35-9. [pmid: 12590621].
197 Nobuhara K, Okugawa G, Minami T, Takase K, Yoshida T, Yagyu T, et al. Effects of electroconvulsive therapy on frontal white matter in late-life depression: a diffusion tensor imaging study. Neuropsychobiology. 2004:48-53.
198 Nyhuis PW, Gastpar M, Scherbaum N. Opiate treatment in depression refractory to antidepressants and electroconvulsive therapy. J Clin Psychopharmacol. Oct. 2008;28(5):593-5. [pmid: 18794671].
199 O'Connor MK, Knapp R, Husain M, Rummans TA, Petrides G, Smith G, et al. The influence of age on the response of major depression to electroconvulsive therapy: a C.O.R.E. Report. Am J Geriatr Psychiatry. Fall. 2001;9(4):382-90. [pmid: 11739064].
200 Okamoto T, Yoshimura R, Ikenouchi-Sugita A, Hori H, Umene-Nakano W, Inoue Y, et al. Efficacy of electroconvulsive therapy is associated with changing blood levels of homovanillic acid and brain-derived neurotrophic factor (BDNF) in refractory depressed patients: a pilot study. Prog Neuropsychopharmacol Biol Psychiatry. Jul. 1. 2008;32(5):1185-90. [pmid: 18403081].
201 Okazaki M, Tominaga K, Higuchi H, Utagawa I, Nakamura E, Noguchi M, et al. Predictors of response to electroconvulsive therapy obtained using the three-factor structure of the Montgomery and Asberg Depression Rating Scale for treatment-resistant depressed patients. J Ect Jun. 26(2):87-90.
202 Oquendo MA, Malone KM, Ellis SP, Sackeim HA, Mann JJ. Inadequacy of antidepressant treatment for patients with major depression who are at risk for suicidal behavior. American Journal of Psychiatry. 1999;156(2):190-4. [pmid: 9989553].
203 Ozsoy S, Esel E, Kula M. Serum oxytocin levels in patients with depression and the effects of gender and antidepressant treatment. Psychiatry Res. 2009:249-52.
204 Parker G, Roy K, Hadzi-Pavlovic D, Pedic F. Psychotic (delusional) depression: A meta-analysis of physical treatments. Journal of Affective Disorders. 1992;24(1):17-24. [pmid: 1347545].
205 Parker V, Nobler MS, Pedley TA, Sackeim HA. A unilateral, prolonged, nonconvulsive seizure in a patient treated with bilateral ECT. J Ect. 2001:141-5.
206 Pascual-Leone A, Houser CM, Reese K, Shotland LI, Grafman J, Sato S, et al. Safety of rapid-rate transcranial magnetic stimulation in normal volunteers. Electroencephalography and Clinical Neurophysiology - Electromyography and Motor Control. 1993;89(2):120-30.
207 Pascual-Leone A, Tormos JM, Keenan J, Tarazona F, Cañete C, Catalá MD. Study and modulation of human cortical excitability with transcranial magnetic stimulation. Journal of Clinical Neurophysiology. 1998;15(4):333-43. [pmid: 9736467].
208 Paul SM, Extein I, Calil HM. Use of ECT with treatment-resistant depressed patients at the National Institute of Mental Health. American Journal of Psychiatry. 1981;138(4):486-9. [pmid: 6111228].
209 Paykel ES, Scott J, Cornwall PL, Abbott R, Crane C, Pope M, et al. Duration of relapse prevention after cognitive therapy in residual depression: follow-up of controlled trial. Psychol Med. 2005/04/22. 2005:59-68.
210 Paykel ES, Scott J, Teasdale JD, Johnson AL, Garland A, Moore R, et al. Prevention of relapse in residual depression by cognitive therapy. A controlled trial. Archives of General Psychiatry. 1999;56(9):829-35. [pmid: 12884889].
211 Perez V, Gilaberte I, Faries D, Alvarez E, Artigas F. Randomised, double-blind, placebo-controlled trial of pindolol in combination with fluoxetine antidepressant treatment. Lancet. May. 31. 1997;349(9065):1594-7. [pmid: 9174562].
212 Peselow ED, Filippi AM, Goodnick P, Barouche F, Fieve RR. The short- and long-term efficacy of paroxetine HCl: B. Data from a double-blind crossover study and from a year-long term trial vs. imipramine and placebo. Psychopharmacol Bull. 1989/01/01. 1989:272-6.
213 Peselow ED, Filippi AM, Goodnick P, Barouche F, Fieve RR. The short- and long-term efficacy of paroxetine HCl: A. Data from a 6-week double-blind parallel design trial vs. imipramine and placebo. Psychopharmacol Bull. 1989;25(2):267-71. [pmid: 2532373].
214 Philibert RA, Richards L, Lynch CF, Winokur G. Effect of ECT on mortality and clinical outcome in geriatric unipolar depression. Journal of Clinical Psychiatry. 1995;56(7 SUPPL.):390-4. [pmid: 7665536].
215 Poirier MF. [The concept of resistant depression and therapeutic strategies, particularly, with venlafaxine]. Encephale. Jun. 1999;25(Spec No 2):55-7. discussion 8-61. [pmid: 10434160].
216 Pope HG Jr, McElroy SL, Nixon RA. Possible synergism between fluoxetine and lithium in refractory depression. Am J Psychiatry. Oct. 1988;145(10):1292-4. [pmid: 3262313].
217 Prudic J, Sackeim HA, Devanand DP. Medication resistance and clinical response to electroconvulsive therapy. Psychiatry Research. 1990;31(3):287-96. [pmid: 1970656].
218 Ramasubbu R. Treatment of resistant depression by adding noradrenergic agents to lithium augmentation of SSRIs. Ann Pharmacother. Apr. 2002;36(4):634-40. [pmid: 11918513].
219 Rapaport MH, Gharabawi GM, Canuso CM, Mahmoud RA, Keller MB, Bossie CA, et al. Effects of risperidone augmentation in patients with treatment-resistant depression: Results of open-label treatment followed by double-blind continuation. Neuropsychopharmacology. 2006/06/09. 2006:2505-13.
220 Rasanen P, Hakko H, Tiihonen J. Mitchell B. Balter Award--1998. Pindolol and major affective disorders: a three-year follow-up study of 30,485 patients. J Clin Psychopharmacol. Aug. 1999;19(4):297-302. [pmid: 10440455].
221 Rasmussen KG, Karpyak VM, Hammill SC. Lack of effect of ECT on Holter monitor recordings before and after treatment. J Ect. Mar. 2004;20(1):45-7. [pmid: 15087997].
222 Rasmussen KG, Mueller M, Kellner CH, Knapp RG, Petrides G, Rummans TA, et al. Patterns of psychotropic medication use among patients with severe depression referred for electroconvulsive therapy: data from the Consortium for Research on Electroconvulsive Therapy. J Ect. Jun. 2006;22(2):116-23. [pmid: 16801827].
223 Rasmussen P, Andersson JE, Koch P, Secher NH, Quistorff B. Glycopyrrolate prevents extreme bradycardia and cerebral deoxygenation during electroconvulsive therapy. J Ect. Sep. 2007;23(3):147-52. [pmid: 17804987].
224 Rehor G, Conca A, Schlotter W, Vonthein R, Bork S, Bode R, et al. [Relapse rate within 6 months after successful ECT: a naturalistic prospective peer- and self-assessment analysis]. Neuropsychiatr. 2009:157-63.
225 Reynaert-Dupuis C, Zdanowicz N, Group AG-BS, Leyman S, Mignon A, Seghers S. Efficacy and tolerance of venlafaxine in depressed patients switched from prior antidepressant treatment. PRIMARY CARE PSYCHIATRY. 2002;8:63-8.
226 Reynolds CF III, Frank E, Houck PR, Mazumdar S, Dew MA, Cornes C, et al. Which elderly patients with remitted depression remain well with continued interpersonal psychotherapy after discontinuation of antidepressant medication?. American Journal of Psychiatry. 1997;154(7):958-62. [pmid: 9210746].
227 Reynolds CF III, Frank E, Kupfer DJ, Thase ME, Perel JM, Mazumdar S, et al. Treatment outcome in recurrent major depression: A post hoc comparison of elderly (‘young old’) and midlife patients. American Journal of Psychiatry. 1996;153(10):1288-92. [pmid: 8831436].
228 Reynolds CF III, Frank E, Perel JM, Mazumdar S, Dew MA, Begley A, et al. High relapse rate after discontinuation of adjunctive medication for elderly patients with recurrent major depression. American Journal of Psychiatry. 1996;153(11):1418-22. [pmid: 8890674].
229 Reynolds CF III, Miller MD, Pasternak RE, Frank E, Perel JM, Cornes C, et al. Treatment of bereavement-related major depressive episodes in later life: A controlled study of acute and continuation treatment with nortriptyline and interpersonal psychotherapy. American Journal of Psychiatry. 1999;156(2):202-8. [pmid: 9989555].
230 Reynolds CF I, Frank E, Perel JM, Imber SD, Cornes C, Miller MD, et al. Nortriptyline and interpersonal psychotherapy as maintenance therapies for recurrent major depression. A randomized controlled trial in patients older than 59 years. Journal of the American Medical Association. 1999;281(1):39-45. [pmid: 9892449].
231 Reynolds CF I, Frank E, Perel JM, Miller MD, Cornes C, Rifai AH, et al. Treatment of consecutive episodes of major depression in the elderly. American Journal of Psychiatry. 1994;151(12):1740-3. [pmid: 7977879].
232 Rich CL, Spiker DG, Jewell SW. The efficiency of ECT: I. Response rate in depressive episodes. Psychiatry Research. 1984;11(3):167-76. [pmid: 6587410].
233 Robin A, Harris JA. A controlled comparison of imipramine and electroplexy. J Ment Sci. 1962;108:217-9. [pmid: 14492854].
234 Rocha FL, Hara C. Lamotrigine augmentation in unipolar depression. Int Clin Psychopharmacol. Mar. 2003;18(2):97-9. [pmid: 12598821].
235 Roose SP. Methodological issues in the diagnosis, treatment, and study of refractory depression. Treatment Strategies for Refractory Depression. 1990:1-9.
236 Rosa MA, Rosa MO, Daltio CS, Abreu LN, Marcolin MA. Open trial on the efficacy of right unilateral electroconvulsive therapy with titration and high charge. J Ect. Dec. 2006;22(4):237-9. [pmid: 17143152].
237 Ross J. Discontinuation of lithium augmentation in geriatric patients with unipolar depression: a systematic review. Can J Psychiatry. Feb. 2008;53(2):117-20. [pmid: 18357930].
238 Rossi S, Hallett M, Rossini PM, Pascual-Leone A. Safety, ethical considerations, and application guidelines for the use of transcranial magnetic stimulation in clinical practice and research. Clin Neurophysiol. Dec. 2009;120(12):2008-39. [pmid: 19833552].
239 Rothschild AJ, Williamson DJ, Tohen MF, Schatzberg A, Andersen SW, Van Campen LE, et al. A double-blind, randomized study of olanzapine and olanzapine/fluoxetine combination for major depression with psychotic features. J Clin Psychopharmacol. Aug. 2004;24(4):365-73. [pmid: 15232326].
240 Ruhwinkel B, Tolle R. [Modified insulin treatment of therapy refractory depression]. Psychiatr Prax. Mar. 1995;22(2):64-7. [pmid: 7761541].
241 Rush AJ, George MS, Sackeim HA, Marangell LB, Husain MM, Giller C, et al. Vagus nerve stimulation (VNS) for treatment-resistant depressions: a multicenter study. Biological Psychiatry. 2000;47(4):276-86. [pmid: 10686262].
242 Rush AJ, Gullion CM, Roffwarg HP. When do patients respond to tricyclic antidepressants? Biol Psychiatry. 1994;35:711-7.
243 Rush AJ, Trivedi MH, Wisniewski SR, Nierenberg AA, Stewart JW, Warden D, et al. Acute and longer-term outcomes in depressed outpatients requiring one or several treatment steps: A STAR*D report. American Journal of Psychiatry. 2006;163(11):1905-17. [pmid: 17074942].
244 Rush AJ, Trivedi MH, Wisniewski SR, Stewart JW, Nierenberg AA, Thase ME, et al. Bupropion-SR, sertraline, or venlafaxine-XR after failure of SSRIs for depression. N Engl J Med. Mar. 23. 2006;354(12):1231-42. [pmid: 16554525].
245 Sackeim HA. Magnetic stimulation therapy and ECT. Convuls Ther. 1994;10(4):255-8.
246 Sackeim HA. Repetitive transcranial magnetic stimulation: What are the next steps? Biological Psychiatry. 2000;48(10):959-61.
247 Sackeim HA. Memory and ECT: from polarization to reconciliation. J ECT. 2000;16(2):87-96. [pmid: 10868319].
248 Sackeim HA, Portnoy S, Neeley P. Cognitive consequences of low-dosage electroconvulsive therapy. Annals of the New York Academy of Sciences. 1986;462:326-40. [pmid: 3458413].
249 Saijo T, Takano A, Suhara T, Arakawa R, Okumura M, Ichimiya T, et al. Effect of electroconvulsive therapy on 5-HT1A receptor binding in patients with depression: a PET study with [11C]WAY 100635. Int J Neuropsychopharmacol Jul. 13(6):785-91.
250 Saito S, Takahashi N, Ishihara R, Ikeda M, Suzuki T, Kitajima T, et al. Association study between vesicle-associated membrane protein 2 gene polymorphisms and fluvoxamine response in Japanese major depressive patients. Neuropsychobiology. 2006;54(4):226-30. [pmid: 17356306].
251 Salinsky MC. A randomized controlled trial of chronic vagus nerve stimulation for treatment of medically intractable seizures. Neurology. 1995;45(2):224-30. [pmid: 7854516].
252 Santos MA, Rocha FL, Hara C. Efficacy and safety of antidepressant augmentation with lamotrigine in patients with treatment-resistant depression: A randomized, placebo-controlled, double-blind study. Primary Care Companion to the Journal of Clinical Psychiatry. 2008;10(3):187-90.
253 Schatzberg AF, Rush AJ, Arnow BA, Banks PL, Blalock JA, Borian FE, et al. Chronic depression: medication (nefazodone) or psychotherapy (CBASP) is effective when the other is not. Arch Gen Psychiatry. May. 2005;62(5):513-20. [pmid: 15867104].
254 Schneider F, Harter M, Brand S, Sitta P, Menke R, Hammer-Filipiak U, et al. Adherence to guidelines for treatment of depression in in-patients. Br J Psychiatry. Nov. 2005;187:462-9. [pmid: 16260823].
255 Schneider LS, Sloane RB, Staples FR, Bender M. Pretreatment orthostatic hypotension as a predictor of response to nortriptyline in geriatric depression. Journal of Clinical Psychopharmacology. 1986;6(3):172-6. [pmid: 3711368].
256 Schweitzer I, Tuckwell V. Risk of adverse events with the use of augmentation therapy for the treatment of resistant depression. Drug Saf. Dec. 1998;19(6):455-64. [pmid: 9880089].
257 Scott AIF, Freeman CPL. Edinburgh primary care depression study: Treatment outcome, patient satisfaction, and cost after 16 weeks. British Medical Journal. 1992;304(6831):883-7. [pmid: 1392754].
258 Scott J. Treatment of chronic depression. New England Journal of Medicine. 2000;342(20):1518-20. [pmid: 10816192].
259 Scott J, Teasdale JD, Paykel ES, Johnson AL, Abbott R, Hayhurst H, et al. Effects of cognitive therapy on psychological symptoms and social functioning in residual. British Journal of Psychiatry. NOV. 2000;177:440-6. [pmid: 11059998].
260 Segui J, Lopez-Munoz F, Alamo C, Camarasa X, Garcia-Garcia P, Pardo A. Effects of adjunctive reboxetine in patients with duloxetine-resistant depression: a 12-week prospective study. J Psychopharmacol. Aug. 2010;24(8):1201-7. [pmid: 19282423].
261 Seth R, Jennings AL, Bindman J, Phillips J, Bergmann K. Combination treatment with noradrenalin and serotonin reuptake inhibitors in resistant depression. Br J Psychiatry. Oct. 1992;161:562-5. [pmid: 1327396].
262 Shafique S, Dalsing MC. Vagus nerve stimulation therapy for treatment of drug-resistant epilepsy and depression. Perspect Vasc Surg Endovasc Ther. Dec. 2006;18(4):323-7. [pmid: 17351201].
263 Shuchman M. Approving the vagus-nerve stimulator for depression. New England Journal of Medicine. 2007;356(16):1604-7. [pmid: 17442903].
264 Simpson KN, Welch MJ, Kozel FA, Demitrack MA, Nahas Z. Cost-effectiveness of transcranial magnetic stimulation in the treatment of major depression: a health economics analysis. Adv Ther. Mar. 2009;26(3):346-68. [pmid: 19330495].
265 Sokolski KN. Adjunctive aripiprazole for bupropion-resistant major depression. Annals of Pharmacotherapy (USA). 01/01/. 2008;42(Feb):1124-9.
266 Solvason HB, Husain M, Fitzgerald PB, Rosequist P, McCall V, Kimball J, et al. TMS in the acute treatment of major depression: Improvments in functional status and quality of life. Society fo Bilogical Psychiatry Annual Meeting. San Diego, CA. 2007.
267 Souza FG, Goodwin GM. Lithium treatment and prophylaxis in unipolar depression: a meta-analysis. Br J Psychiatry. May. 1991;158:666-75. [pmid: 1830506].
268 Spitzer RL, National Institute of Mental Health (U.S.). User's guide for the structured clinical interview for DSM-III-R: SCID. Washington, DC. American Psychiatric Press. 1990.
269 Stanley W, Fleming H. A clinical comparison of phenelzine and electro-convulsive therapy in the treatment of depressive illness. Br J Psychiatry. 1962;108:708-10.
270 Stein G, Bernadt M. Lithium augmentation therapy in tricyclic-resistant depression. A controlled trial using lithium in low and normal doses. Br J Psychiatry. May. 1993;162:634-40. [pmid: 8149115].
271 Steiner M, Radwan M, Elizur A. Failure of L-triiodothyronine (T3) to potentiate tricyclic antidepressant response. Current Therapeutic Research - Clinical and Experimental. 1978;23(5 II):655-9.
272 Sterling P. ECT damage is easy to find if you took for it [3]. Nature. 2000;403(6767):242. [pmid: 10659824].
273 Steuer JL, Mintz J, Hammen CL. Cognitive-behavioral and psychodynamic group psychotherapy in treatment of geriatric depression. Journal of Consulting and Clinical Psychology. 1984;52(2):180-9. [pmid: 6715645].
274 Stimpson N, Agrawal N, Lewis G. Randomised controlled trials investigating pharmacological and psychological interventions for treatment-refractory depression. British Journal of Psychiatry. 2002;181:284-94. [pmid: 12356654].
275 Strömgren LS. Unilateral versus bilateral electroconvulsive therapy. Investigations into the therapeutic effect in endogenous depression. Acta Psychiatrica Scandinavica, Supplement. 1973;240:8-65.
276 Szabo K, Hirsch JG, Krause M, Ende G, Henn FA, Sartorius A, et al. Diffusion weighted MRI in the early phase after electroconvulsive therapy. Neurol Res. Apr. 2007;29(3):256-9. [pmid: 17509223].
277 Taylor MA, Abrams R. Short-term cognitive effects of unilateral and bilateral ECT. British Journal of Psychiatry. 1985;146(MAR.):308-11. [pmid: 3986441].
278 Taylor MP, Reynolds CE III, Frank E, Cornes C, Miller MD, Stack JA, et al. Which elderly depressed patients remain well on maintenance interpersonal psychotherapy alone?: Report from the Pittsburgh Study of Maintenance Therapies in late-life depression. Depression and Anxiety. 1999;10(2):55-60. [pmid: 10569127].
279 Teasdale JD, Scott J, Moore RG, Hayhurst H, Pope M, Paykel ES. How does cognitive therapy prevent relapse in residual depression? Evidence from a controlled trial. J Consult Clin Psychol. Jun. 2001;69(3):347-57. [pmid: 11495165].
280 Thase ME Jr, Rush AJ Jr. Treatment-resistant depression. Treatment-Resistant Depression in Psychopharmacology: The Fourth Generation of Progress. 1995.
281 Thase ME, Blomgren SL, Birkett MA, Apter JT, Tepner RG. Fluoxetine treatment of patients with major depressive disorder who failed initial treatment with sertraline. J Clin Psychiatry. Jan. 1997;58(1):16-21. [pmid: 9055832].
282 Thase ME, Entsuah AR, Rudolph RL. Remission rates during treatment with venlafaxine or selective serotonin reuptake inhibitors. British Journal of Psychiatry. 2001;178(MARCH):234-41. [pmid: 11230034].
283 Thase ME, Ferguson JM, Lydiard RB, Wilcox CS. Citalopram treatment of paroxetine-intolerant depressed patients. Depress Anxiety. 2002;16(3):128-33. [pmid: 12415538].
284 Thase ME, Friedman ES, Biggs MM, Wisniewski SR, Trivedi MH, Luther JF, et al. Cognitive therapy versus medication in augmentation and switch strategies as second-step treatments: a STAR*D report. Am J Psychiatry. 2007:739-52.
285 Thase ME, Greenhouse JB, Frank E, Reynolds CF 3rd, Pilkonis PA, Hurley K, et al. Treatment of major depression with psychotherapy or psychotherapy-pharmacotherapy combinations. Arch Gen Psychiatry. Nov. 1997;54(11):1009-15. [pmid: 9366657].
286 Thase ME, Simons AD, McGeary J, Cahalane JF, Hughes C, Harden T, et al. Relapse after cognitive behavior therapy of depression: Potential implications for longer courses of treatment. American Journal of Psychiatry. 1992;149(8):1046-52. [pmid: 1636804].
287 Thiery M. Clinical trial of the treatment of depressive illness. BMJ. 1965;1:881-6. [pmid: 14257398].
288 Thomas SA, Lincoln NB. Factors relating to depression after stroke. Clinical Rehabilitation. 2004;18(5):589-90.
289 Thomas SA, Lincoln NB. Factors relating to depression after stroke. British Journal of Clinical Psychology. 2006;45(1):49-61. [pmid: 16480566].
290 Thompson LW, Gallagher D, Breckenridge JS. Comparative effectiveness of psychotherapies for depressed elders. Journal of Consulting and Clinical Psychology. 1987;55(3):385-90. [pmid: 3597953].
291 Tome MB, Isaac MT, Harte R, Holland C. Paroxetine and pindolol: a randomized trial of serotonergic autoreceptor blockade in the reduction of antidepressant latency. Int Clin Psychopharmacol. Mar. 1997;12(2):81-9. [pmid: 9219043].
292 Trivedi MH, Fava M, Wisniewski SR, Thase ME, Quitkin F, Warden D, et al. Medication augmentation after the failure of SSRIs for depression. N Engl J Med. Mar. 23. 2006;354(12):1243-52. [pmid: 16554526].
293 Usui C, Doi N, Nishioka M, Komatsu H, Yamamoto R, Ohkubo T, et al. Electroconvulsive therapy improves severe pain associated with fibromyalgia. Pain. Apr. 2006;121(3):276-80. [pmid: 16495009].
294 Valentine M, Keddie KM, Dunne D. A comparison of techniques in electroconvulsive therapy. British Journal of Psychiatry. 1968;114(513):989-96. [pmid: 4879295].
295 Van Schaik A, Van Marwijk H, Adèr H, Van Dyck R, De Haan M, Penninx B, et al. Interpersonal psychotherapy for elderly patients in primary care. American Journal of Geriatric Psychiatry. 2006;14(9):777-86. [pmid: 16943174].
296 Vandoolaeghe E, Maes M, Vandevyvere J, Neels H. Hypothalamic-pituitary-thyroid-axis function in treatment resistant depression. J Affect Disord. Apr. 1997;43(2):143-50. [pmid: 9165383].
297 Wajima Z, Shiga T, Yoshikawa T, Ogura A, Inoue T, Ogawa R. Propofol alone, sevoflurane alone, and combined propofol-sevoflurane anaesthesia in electroconvulsive therapy. Anaesth Intensive Care. Aug. 2003;31(4):396-400. [pmid: 12973963].
298 Walker PW, Cole JO, Gardner EA, Hughes AR, Johnston JA, Batey SR, et al. Improvement in fluoxetine-associated sexual dysfunction in patients switched to bupropion. J Clin Psychiatry. Dec. 1993;54(12):459-65. [pmid: 8276736].
299 Weilburg JB, Rosenbaum JF, Biederman J, Sachs GS, Pollack MH, Kelly K. Fluoxetine added to non-MAOI antidepressants converts nonresponders to responders: a preliminary report. J Clin Psychiatry. Dec. 1989;50(12):447-9. [pmid: 2600061].
300 Weiner RD, Rogers HJ, Davidson JRT, Squire LR. Effects of stimulus parameters on cognitive side effects. Annals of the New York Academy of Sciences. 1986;462:315-25. [pmid: 3458412].
301 Welch CA, Weiner RD, Weir D. Efficacy of ECT in the treatment of depression: Wave form and electrode placement considerations. Psychopharmacology bulletin. 1982;18(1):31-4. [pmid: 7146252].
302 Wells KB, Sturm R, Sherbourne CD, Meredith LS. Caring for Depression. Caring for Depression. 1996.
303 White PF, Amos Q, Zhang Y, Stool L, Husain MM, Thornton L, et al. Anesthetic considerations for magnetic seizure therapy: a novel therapy for severe depression. Anesth Analg. 2006/06/23. 2006:76-80. table of contents.
304 Wijkstra J, Burger H, van den Broek WW, Birkenhager TK, Janzing JG, Boks MP, et al. Treatment of unipolar psychotic depression: a randomized, double-blind study comparing imipramine, venlafaxine, and venlafaxine plus quetiapine. Acta Psychiatr Scand. 2009/08/22. 2010:190-200.
305 Williams N, Simpson AN, Simpson K, Nahas Z. Relapse rates with long-term antidepressant drug therapy: a meta-analysis. Hum Psychopharmacol. 2009/06/16. 2009:401-8.
306 Wilson IC, Vernon JT, Guin T. A controlled study of treatments of depression. J Neuropsychiatry. 1963;4:331-7.
307 Zanardi R, Artigas F, Franchini L, Sforzini L, Gasperini M, Smeraldi E, et al. How long should pindolol be associated with paroxetine to improve the antidepressant response?. J Clin Psychopharmacol. Dec. 1997;17(6):446-50. [pmid: 9408806].
308 Zarate CA, Kando JC, Tohen M, Weiss MK, Cole JO. Does intolerance or lack of response with fluoxetine predict the same will happen with sertraline?. J Clin Psychiatry. Feb. 1996;57(2):67-71. [pmid: 8591971].
309 Zervas IM, Papakostas YG, Theodoropoulou MA, Dimitrakopoulos C, Vaidakis N, Daras M. Thyrotropin-releasing hormone administration does not affect seizure threshold during electroconvulsive therapy. J Ect. Sep. 2003;19(3):136-8. [pmid: 12972982].
310 Zyss T. Deep magnetic brain stimulation - the end of psychiatric electroshock therapy?. Medical Hypotheses. 1994;43(2):69-74. [pmid: 7990740].