# Characteristics of Studies With Poor Internal Validity

To assess the quality (internal validity or risk of bias) of studies, we used predefined criteria based on those described in the AHRQ Methods Guide for Comparative Effectiveness Reviews (ratings: good, fair, poor). Elements of quality assessment for trials included, among others, the methods used for randomization, allocation concealment, and blinding; the similarity of compared groups at baseline; maintenance of comparable groups; overall and differential loss to follow-up; and the use of intention-to-treat analysis. We assessed observational studies based on the potential for selection bias (methods of selection of subjects and loss to followup), potential for measurement bias (equality, validity, and reliability of ascertainment of outcomes), adjustment for potential confounders, and statistical analysis.

In general terms, a “good” study has the least bias and results are considered to be valid. A “fair” study is susceptible to some bias but probably not sufficient to invalidate its results. The fair-quality category is likely to be broad, so studies with this rating will vary in their strengths and weaknesses. A “poor” rating indicates significant bias (stemming from, e.g., serious errors in design, analysis reporting, large amounts of missing information, or discrepancies in reporting) that may invalidate the study's results.

To systematically rate studies, we designed and used a structured data abstraction form. Trained reviewers abstracted data from each study and assigned an initial quality rating. A second reviewer read each abstracted article, evaluated the accuracy, completeness, and consistency of the data abstraction, and independently rated the quality. If differences in quality ratings could not be resolved by discussion, a third senior reviewer was involved. The full research team met regularly during the article abstraction period to discuss global issues related to the data abstraction process. The following lists all the studies reviewed and rated as poor quality, with their design and primary reasons for the final rating.

Study | Design | Primary Reasons for Poor Quality Rating
Key Question 1a
Gregory, 1985^1^ | RCT | High potential for selection bias. Study does not report adequate information for assessment of bias, specifically regarding baseline characteristics. High rate of attrition. Study analysis was on completers only.
Grunhaus, 2000^2^ | RCT | High potential for measurement bias. Patients did not receive the same amount of pulses. One intervention group underwent switch intervention strategy the other intervention group underwent and augmentative intervention strategy.
Wang, 2004^3^ | RCT | High potential for selection bias. This article does not report adequate information for an assessment of bias, particularly regarding baseline differences and patient withdrawal from treatment. Inadequate reporting of randomization.
Key Question 1b
Barker, 1987^4^ | RCT | High potential for selection bias. Study does not report adequate information for an assessment of bias, particularly regarding baseline differences and patient withdrawal from treatment. Inadequate reporting of randomization techniques and reporting of statistical methodology. High attrition and modification of protocol.
Maes, 1996^5^ | RCT | High potential for selection bias. No baseline information provided on TRD only group.
Sunderland, 1994^6^ | RCT | High potential for measurement bias. Study does not report of any washout between crossovers. Study inadequately reports between group differences unable to asses differences on key outcomes (mean change, response, and remission).
Key Question 2
Kauffmann, 2004^7^ | RCT | High potential for measurement bias. Study does not provide numbers or methods for followup.
Key Question 3
Grunhaus, 2000^2^ | RCT | High potential for measurement bias. Patients did not receive the same amount of pulses. One intervention group underwent switch intervention strategy the other intervention group underwent and augmentative intervention strategy.
Key Question 4a
Fitzgerald, 2006^8^ | RCT | High potential for selection and measurement bias. Study poorly reports outcomes and to whom these outcomes are applicable.
Hansen, 2010^9^ | RCT | High potential for selection bias. Analysis was performed on a subgroup of patients.
Frith, 1983; Frith, 1987^10,11^ | RCT | High potential for selection bias. Analyses concerning cognition were done on an undefined subgroup.
Key Question 4b
Bortolomasi, 2007^12^ | RCT | High potential for selection bias and measurement bias. Poor reporting. Study does not provide how adverse events were solicited (i.e., spontaneous admission or solicited by provider). Does not specify whether reports of adverse events were reported by active or sham patients.
Fitzgerald, 2003^13^ | RCT | High potential for selection bias. No systematic method of data collection.
Fitzgerald, 2006^8^ | RCT | High potential for selection bias. No systematic method of data collection.
Grunhaus, 2003^14^ | RCT | High potential for selection bias. No systematic method of data collection.
Hansen, 2010^9^ | RCT | High potential for selection bias. Analysis was performed on a subgroup of patients.
Holtzheimer, 2004^15^ | RCT | High potential for selection and measurement bias. Does not provide how adverse events were solicited (i.e., spontaneous admission or solicited by provider).
Kauffmann, 2004^7^ | RCT | High potential for measurement bias. Does not provide sufficient information to assess quality of data collection on adverse events.
Manes, 2001 16 | RCT | High potential for selection, measurement, and/or confounding bias. No methodology reported.
Padberg, 1999^17^ | RCT | High potential for selection bias. No method of collection reported, it is unclear if pts in sham condition were included in assessment.
Rosa, 2006 18 | RCT | High potential for measurement bias. No systematic method of data collection.
Su, 2005^19^ | RCT | High potential for selection bias. No systematic method of data collection.
Key Question 4d
Grunhaus, 2000^2^ | RCT | High potential for measurement bias. Patients did not receive the same amount of pulses. One intervention group underwent switch intervention strategy. The other intervention group underwent an augmentative intervention strategy.
Key Question 5
Narushima, 2010^20^ | RCT | High potential for selection bias. Inadequate reporting of randomization techniques and reporting of statistical methodology. High rate of differential and overall attrition
Takahashi, 2009^21^ | | High potential for measurement and selection bias. Study does not compare between interventions. Inadequate reporting of randomization techniques.
Key Question 6
Wiles, 2008^22^ | RCT | High potential for measurement bias. Scale used but outcomes not reported.

RCT = randomized controlled trial

## References

1 Gregory S, Shawcross CR, Gill D. The Nottingham ECT study. A double-blind comparison of bilateral, unilateral and simulated ECT in depressive illness. Br J Psychiatry. 1985;146(MAY):520-4. [pmid: 3893601].
2 Grunhaus L, Dannon PN, Schreiber S, et al. Repetitive transcranial magnetic stimulation is as effective as electroconvulsive therapy in the treatment of nondelusional major depressive disorder: an open study. Biol Psychiatry. Feb. 15. 2000;47(4):314-24. [pmid: 10686266].
3 Wang XM, Yang DB, Yu YF, et al. A controlled study of the treatment of repetitive transcranial magnetic stimulation in patients with major depression. Chin J Clin Rehab. 2004;8(9):1770-1.
4 Barker WA, Scott J, Eccleston D. The Newcastle chronic depression study: results of a treatment regime. Int Clin Psychopharmacol. Jul. 1987;2(3):261-72. [pmid: 3121718].
5 Maes M, Vandoolaeghe E, Desnyder R. Efficacy of treatment with trazodone in combination with pindolol or fluoxetine in major depression. J Affect Disord. 1996;41(3):201-10. [pmid: 8988452].
6 Sunderland T, Cohen RM, Molchan S, et al. High-dose selegiline in treatment-resistant older depressive patients. Arch Gen Psychiatry. 1994;51(8):607-15. [pmid: 7519005].
7 Kauffmann CD, Cheema MA, Miller BE. Slow right prefrontal transcranial magnetic stimulation as a treatment for medication-resistant depression: a double-blind, placebo-controlled study. Depression and Anxiety. 2004;19(1):59-62. [pmid: 14978787].
8 Fitzgerald PB, Benitez J, de Castella A, et al. A randomized, controlled trial of sequential bilateral repetitive transcranial magnetic stimulation for treatment-resistant depression. Am J Psychiatry. Jan. 2006;163(1):88-94. [pmid: 16390894].
9 Hansen PE, Ravnkilde B, Videbech P, et al. Low-frequency repetitive transcranial magnetic stimulation inferior to electroconvulsive therapy in treating depression. J ECT. 2010. Mar. 25. [pmid: 20351570].
10 Frith CD, Stevens M, Johnstone EC, et al. A comparison of some retrograde and anterograde effects of electroconvulsive shock in patients with severe depression. Br J Psychol. 1987;78(Pt 1):53-63. [pmid: 3828659].
11 Frith CD, Stevens M, Johnstone EC, et al. Effects of ECT and depression on various aspects of memory. Br J Psychiatry. 1983:142610-7. [pmid: 6882984].
12 Bortolomasi M, Minelli A, Fuggetta G, et al. Long-lasting effects of high frequency repetitive transcranial magnetic stimulation in major depressed patients. Psychiatry Res. Mar. 30. 2007;150(2):181-6. [pmid: 17303249].
13 Fitzgerald PB, Brown TL, Marston NA, et al. Transcranial magnetic stimulation in the treatment of depression: a double-blind, placebo-controlled trial. Arch Gen Psychiatry. Oct. 2003;60(10):1002-8. [pmid: 14557145].
14 Grunhaus L, Schreiber S, Dolberg OT, et al. A randomized controlled comparison of electroconvulsive therapy and repetitive transcranial magnetic stimulation in severe and resistant nonpsychotic major depression. Biol Psychiatry. Feb. 15. 2003;53(4):324-31. [pmid: 12586451].
15 Holtzheimer PE 3rd, Russo J, Claypoole KH, et al. Shorter duration of depressive episode may predict response to repetitive transcranial magnetic stimulation. Depress Anxiety. 2004;19(1):24-30. [pmid: 14978782].
16 Manes F, Jorge R, Morcuende M, et al. A controlled study of repetitive transcranial magnetic stimulation as a treatment of depression in the elderly. Int Psychogeriatr. Jun. 2001. 2001;13(2):225-31. [pmid: 11495396].
17 Padberg F, Zwanzger P, Thoma H, et al. Repetitive transcranial magnetic stimulation (rTMS) in pharmacotherapy-refractory major depression: comparative study of fast, slow and sham rTMS. Psychiatry Res. 1999;88(3):163-71. [pmid: 10622338].
18 Rosa MA, Gattaz WF, Pascual-Leone A, et al. Comparison of repetitive transcranial magnetic stimulation and electroconvulsive therapy in unipolar non-psychotic refractory depression: a randomized, single-blind study. Int J Neuropsychopharmacol. Dec. 2006;9(6):667-76. [pmid: 16923322].
19 Su TP, Huang CC, Wei IH. Add-On rTMS for medication-resistant depression: a randomized, double-blind, sham-controlled trial in Chinese patients. J Clin Psychiatry. Jul. 2005;66(7):930-7. [pmid: 16013911].
20 Narushima K, McCormick LM, Yamada T, et al. Subgenual cingulate theta activity predicts treatment response of repetitive transcranial magnetic stimulation in participants with vascular depression. J Neuropsychiatry Clin Neurosci. 2010;22(1):75-84. [pmid: 20160213].
21 Takahashi S, Mizukami K, Yasuno F, et al. Depression associated with dementia with Lewy bodies (DLB) and the effect of somatotherapy. Psychogeriatrics. 2009;9(2):56-61. [pmid: 19604326].
22 Wiles NJ, Hollinghurst S, Mason V, et al. A randomized controlled trial of cognitive behavioural therapy as an adjunct to pharmacotherapy in primary care based patients with treatment resistant depression: A pilot study. Behav Cognit Psychother. Jan. 2008;36(1):21-33.