# Abbreviations and Full Names of Diagnostic Scales and Other Instruments

Abbreviated Name | Complete Name of Measure or Instrument | Range or mean of Scores | Improvement Denoted by
AMI | Autobiographical Memory Interview 1 | 0–63 | Increase
AMS | Autobiographical Memory Schedule1 | 0–9 | Increase
BSRT | Buschke Selective Reminding Test - 12 free recall trials of a 12 item word list; on each trial the patient is reminded only of items forgotten on the previous trial. 2 | Varies | increase
CVLT | California Verbal Learning Test 3 | Varies- results are based on overall and differences | Increase on overall- decrease on change
CAMCOG | The cognitive and self-contained part of the Cambridge Examination for Mental Disorders of the Elderly4 | 0–107 | Increase
| Digit span forwards5 | 0–16 | Increase
MMSE | Mini-mental state examination6 | 0–30 | Increase
PSMS | Personal Semantic Memory Schedule1 | 0–86 | Increase
RAVLT | Rey Auditory Verbal Learning Test - The RAVLT consists of 15 nouns read aloud for five consecutive trials with each trial followed by a free-recall trial. The total score is the total number of words recalled through the five trials.7 | Varies | Increase
Stroop | The Stroop Color-Word Test8 | Varies | Increase
TMT Part A and B | Trail making test Part A and B 9 | Mean - Part A 29 seconds Part B 75 seconds | Decrease
TNET | Transient News Events Test10 | Varies | Increase

## References

1 Kopelman MD, Wilson BA, Baddeley AD. The autobiographical memory interview: a new assessment of autobiographical and personal semantic memory in amnesic patients. J Clin Exp Neuropsychol. 1989;11(5):724-44. [pmid: 2808661].
2 Buschke H, Fuld PA. Evaluating storage, retention, and retrieval in disordered memory and learning. Neurology. 1974;24(11):1019-25. [pmid: 4473151].
3 Delis DC, Freeland J, Kramer JH, Kaplan E. Integrating clinical assessment with cognitive neuroscience: Construct validation of the California Verbal Learning Test. J Consult Clin Psychol. 1988;56(1):123-30. [pmid: 3346437].
4 De Koning I, Van Kooten F, Dippel DWJ, Van Harskamp F, Grobbee DE, Kluft C, et al. The CAMCOG: A Useful Screening Instrument for Dementia in Stroke Patients. Stroke. 1998;29(10):2080-6. [pmid: 9756586].
5 Wechsler D. Technical manual for the Wechsler Adult Intelligence and Memory Scale. 3. New York. The Psychological Coporation. 1997.
6 Folstein MF, Folstein SE, McHugh PR. “Mini-mental state.” A practical method for grading the cognitive state of patients for the clinician. J Psychiatr Res. Nov. 1975;12(3):189-98. [pmid: 1202204].
7 Lezak MD. Neuropsychological assessment. New York. Oxford University Press. 1995.
8 Golden CJ, Freshwater SM. Stroop color and word test : a manual for clinical and experimental uses. Chicago. Stoelting. 2002.
9 Corrigan JD, Hinkeldey NS. Relationships between parts A and B of the Trail Making Test. Journal Of Clinical Psychology. 1987;43(4):402-9. [pmid: 3611374].
10 O'Connor MG, Sieggreen MA, Bachna K, et al. Long-term retention of transient news events. Journal of the International Neuropsychological Society. 2000;6(1):44-51. [pmid: 10761366].