# Evidence Tables

Evidence Table 1 KQ1 head to head: Tier 1

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Pridmore, 2000^1^ Country, Setting Australia, University of Tasmania, Psychological Medicine, Royal Hobart Hospital, inpatient and outpatient Funding NR Research Objective To determine whether rTMS treatments could be substituted for ECT treatments in a course of ECT, without loss of antidepressant effect, and without increase in subjective side-effects. Quality Rating Fair | Study Design RCT Type of Analysis ITT N 22 Duration Primary outcome after 2 weeks of txt Interventions G1: ECT Only G2: ECT + rTMS Medications Allowed Pts taking antidepressants or mood stabilizers were allowed to continue on these. Not all patients were taking medication at entry. All other psychotropics were ceased 1 week prior to txt initiation Parameters ECT:; - % receiving bilateral: 0; - Intensity: percentage of 504mC equivalent to age of patient.; - Number of sessions (range, mean, SD): 3 times/wk for 2wks; rTMS:; - Frequency (Hz):20; - Motor threshold (%):100; - Number of trains: 30; - Length of train (seconds): 2; - Inter-train interval:20; - Pulses per session: 1200; - Total number of sessions: 4/wk with 1 UL ECT; Strategy Mixed | TRD Definition; - 2+ failed ADs from 2+ drug classes (after 1+ month trials at the max manufacturer recommended dose); - Not required to be in current episode; Tier 1 Inclusion Criteria; - MDD DSM-IV; - Right- handed; - Age 25-70; - Physically well and; - free of epilepsy and intracranial metal objects; - exceed both 26 on MADRS and 18 on HAM-D17; Exclusion Criteria NR | Treatment Failure Mean failed trials NR Polarity, % 100% MDD Age, median yrs G1: 47.1 (48) G2: 44.0 (46) Sex, % females G1: 54.5% G2: 45.4% Right Handed, % 100% HAM-D 17 Baseline n G1: 11 G2: 11 Baseline score, median (SD) G1: 30 G2: 28 MADRS Baseline n G1: 11 G2: 11 Baseline score, mean (SD) G1: 40 G2: 40 Responders, n Baseline n G1: 11 G2: 11 Baseline score, mean (SD) G1: 9.3 G2: 8.3 | HAM-D17 Endpoint score, median (SD) At week 1 G1: 14 G2: 15 At week 2 G1: 7 G2: 8 Change, mean (SD) At week 1 G1: -16 G2: -13′ P = 0.3 At week 2 G1: -23 G2: -20 P = 0.6 Remission HAM-D17<9 G1: 6 (54.5%) G2: 6 (54.5%) P = NR MADRS Endpoint score, mean (SD) At week 1 G1: 17 G2: 20 At week 2 G1: 12 G2: 11 Change, mean (SD) At week 1 G1: -23 G2: -20 P = 0.1 At week 2 G1: -28 G2: -29 P = 0.5 Responders, n G1: 6 (54.5%) G2: 6 (54.5%) Endpoint score, mean (SD) At week 1 G1: 6.2, G2: 6.4 At week 2 G1: 3.0 G2: 5.0 Change, mean (SD) At week 1 G1: -3.1G2: -1.9 At week 2 G1: -6.3 G2: -3.3 | Quality of Life Global Assessment of Functioning (GAF) Baseline n G1: 11 G2: 11 Baseline score, mean (SD) G1: 41 G2: 41 Endpoint score, mean (SD) At week 1 G1: 55 G2: 55 At week 2 G1: 70 G2: 65 Change, mean (SD) At week 1 G1: +14 G2: +14 At week 2 G1: +29 G2: +24; - Median scores are reported; none of P values were significant; - Comparison of gains made by ECT vs. ECT + rTMS: Awk 1 = P = 0.6, CI -13 - 12, Awk2 = P =0.2, CI -4 - 17, Awk1 +Awk2 = P = 0.4, CI = --8 - 17; - Median scores are reported; none of P values were significant; - Comparison of gains made by ECT vs. ECT + rTMS: Awk 1 = P = 0.6, CI -13 - 12, Awk2 = P =0.2, CI -4 - 17, Awk1 +Awk2 = P = 0.4, CI = --8 - 17.; Adverse Events Overall, % Positive responses G1: 56 G2: 31 Amnesia, % Memory Problems At Week 1 G1: 8 r, G2: 3G1:: 9 G2: 4 Headache, responses At Week 1 G1: 8 G2: 5 At Week 2 G1: 9 G2: 6; - None of observed differences in proportions of patients having side effects were statistically significant, as judged by Fisher's exact test; - It should be noted that due to small sample sizes, chance of detecting massive differences was small; - At both assessments (week 1 and week 2), “memory problems” were more than twice as common inECT only stream compared to ECT + rTMS; - Due to small sample sizes, statistical tests cannot exclude possiblity that difference is due to chance. muscle pains; - ECT group, wk 1 = 7 responses, wk 2 = 6 responses; ECT + rTMS,wk 1 = 4, wk 2 = 4.; Attrition NR Adherence/ compliance NR
Author, Year Rosa et al., 2006^2^ Country, setting Brazil, university clinic, inpatients and outpatients included Funding Not reported Research Objective To Compare efficacy and side effects associated with rTMS and ECT in an adult population with TRD Quality Rating Fair | Study design RCT Type of analysis Included completers analysis & ITT (LOCF), ITT is reported in abstraction N 42 Duration Active txt 2-4wks (rTMS pts not responding after 2 wks switched over to ECT), Primary Outcome: HAM-D response at 4wk Interventions G1: ECT G2: rTMS Medications allowed ADs, antipsychotics, mood stabilizers were discontinued while anti-anxiety meds were allowed/initiated as needed Strategy Switch Parameters rTMS:; - Frequency (Hz):10; - Motor threshold (%): 100; - Number of trains: 25; - Length of train (seconds): 10; - Inter-train interval: 20; - Pulses per session: 2500; - Total number of sessions: 20 over 4 wks; ECT:; - % receiving bilateral: NR; - Intensity: 4.5 times threshold; - Number of sessions (range, mean, SD): 10 (1.5) | TRD definition; - A lack of response to at 2+ antidepressants of different classes used for at least 4 wk with adequate dosages, with augmentation (with lithium or thyroid hormone for at least 1 trial); - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - Age 18-65; - unipolar depressive disorder (Ham-D >=22) w/o psychotic symptoms; Exclusion criteria; - History of epilepsy, neurosurgery with presence of metal clips, other neurological or psychiatric disease; - Use of cardiac pacemaker; - Pregnancy | Treatment Failure Previous treatment, not specified, % Overall:100% Polarity, % Unipolar Overal: 100% Age, mean yrs G1: 46.0 G2: 41.8 Sex, % females G1: 46.7 G2: 60.0 Race, % white G1: 80.0 G2: 90.0 HAM-D 17 Baseline n G1: 20 G2: 22 Baseline score, mean (SD) G1: 32.1 (5.0) [based on completers N = 15] G2: 30.1 (4.7) [N = 20] CGI Baseline n G1: 20 (N analyzed =15) G2: 22 (N analyzed =20) Baseline score, mean (SD) G1: 4.7 (0.8) G2: 4.3 (0.8) | HAM-D 17 Endpoint score, mean (SD) NR (graph only) Change, mean (SD) NR (graph only) P = 0.86 Responders, n (%) G1: 6 (20) G2: 10 (45) P = 0.35 Remitters, n (%) Ham-D17 <= 7 G1: 3 (15) G2: 2 (9) P = 0.65 Instrument CGI Endpoint score, mean (SD) 2wk G1: 4.0 (1.0) G2: 3.7 (1.1) 4wk G1: 3.2 (1.5) G2: 3.1 (1.3) Change, mean (SD) NR, P = 0.672 | Quality of Life NR Adverse Events Overall, % NR Suicidality, % G1: 10.0 G2: 9.1 rTMS: 2 pts developed new psychological symptoms (i.e. 1 = dissociative state, 1 = hypomanic symptoms) and were removed from study Neuropsychological or executive functioning; - NS differences between groups on all neuropsychological tests following wk2 & wk4. (Weschler Adult Intelligence Scale - R subtests (Vocabulary, Cube),; - Wechsler Memory Scale subtest (Digit Span),; - Rivermead Behavioral Memory Test); MMSE NR Other Attrition Overall, % 16.7 At end of treatment, % G1: 15.0* G2: 9.1* *Prior to completing txt (txt end date differed by pt) At end of follow-up, % G1: 25.0 G2: 9.1 Withdrawals due to efficacy, % G1: NR G2: 0.0 Withdrawals due to adverse events, % G1: NR G2: 9.1 Other For ECT, 3 were removed by their treating clinician w/o explanation or evaluation of efficacy Adherence/ compliance NR

Evidence Table 2 KQ1 head to head: Tier 2

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Grunhaus et al., 2003^3^ Country, setting Israel, single center, inpatients and outpatients Funding National Association for Research in Schizophrenia and Affective Disorders & Stanley Foundation Research Objective To compare antidepressant efficacy of rTMS and ECT in nonpsychotic major depression Quality Rating Fair | Study design RCT Type of analysis cannot tell, all reported patients included in analysis N 40 Duration Primary outcome after 4 weeks of txt Medications Allowed Patients in both groups required to taper psychotropic medications. Only lorazepram allowed regularly, benzodiazepine allowed only for sleep induction Strategy Switch Interventions G1: ECT G2: rTMS Parameters rTMS; - Frequency (Hz): 10; - Motor threshold (%):90; - Number of trains: 20; - Length of train (seconds): 6; - Inter-train interval:60; - Pulses per session:1200; - Total number of sessions: 5/ wk over 4 wks; ECT:; - % receiving bilateral: 35; - Intensity: 2.5 times seizure threshold; - Number of sessions (range, mean, SD): 10.25 (3.1) | TRD definition All pts referred for ECT following a failure of 1+ AD (at adequate levels and for at least 4 weeks of txt) Tier 2 Inclusion criteria; - Age 18+; - Unipolar major depresssion (DSM IV); - HAM-D >= 18; Exclusion criteria; - Any exclusion criteria for safety of rTMS; - major depression was secondary to a general medical condition or substance abuse; - pts with additional Axis I diagnoses | Treatment Failure Failed 2 or more, % G1: 60 G2: 65 Polarity, % 100% MDD Age, mean yrs G1: 61,4 G2: 57.6 Sex, % females G1: 75 G2: 70 HAM-D 17 Baseline n G1: 20 G2: 20 Baseline score, mean (SD) G1: 25.5 (5.9) G2: 24.4 (3.9) | HAM-D 17 Endpoint score, mean (SD): At week 2 G1: 15.9 (6.6) G2: 14.7 (8.8) At week 4 G1: 13.2 (6.6) G2: 13.3 (9.2) Change, mean (SD) At week 2 G1: -9.6 G2: -9.7 At week 4 G1: -12.3 G2: -11.1 Responders, n Response defined as a decrease ≥ 50% or HAM-D17 score ≤ 10 and a GAF rating ≥ 60 G1: 12 (60%) G2: 11 (55%) P = NS Remitters, n HAM-D17 ≤ 8 G1: 6 (30%) G2: 6 (30%) P = NS | Quality of Life Scale GAF Baseline n G1: 20 G2: 20 Baseline score, mean (SD) G1: 39.8 (9.3) G2: 48.9 (10.8) Endpoint score, mean (SD) At week 2 G1: 55 (12.4) G2: 58.3 (17.1) At week 4 G1: 60.6 (13.5) G2: 62.5 (18.8) Change, mean (SD) b-week 2 G1: -15.2 G2: -9.4 b-week 4 G1: -20.8 G2: -13.6 Scale Pittsburgh Sleep Quality Index Baseline n G1: 20 G2: 20 Baseline score, mean (SD) G1: 12.2 (4.5) G2: 10.4 (4.6) Endpoint score, mean (SD) At week 2 G1: 8.3 (3.9) G2: 9.9 (5.1) At week 4 G1: 8.6 (4.9) G2: 9.4 (5.0) Change, mean (SD) b- week 2 G1: 3.9 G2: 0.5 B week 4 G1: 3.6 G2: 1.0 Adverse Events Overall, % G1: NR “the ECT group was handled clinically and no special recording of side effects was done G2: NR Headache, % G1: NR G2: 15.0 Sleep disturbance: G1: NR G2:10% Neuropsychological or executive functioning Measures, Results Predefined MMSE Baseline n G1: 20 G2: 20 Baseline score, mean (SD) G1: 25.8 (3.4) G2: 27.8 (3.0) Endpoint score, mean (SD) At week 2 G1: 26.3 (2.9) G2: 28.0(2.1) At week 4 G1: 27.1(2.5) G2: 28.0 (1.8) Change, mean (SD) b-week 2 G1: -0.5 G2: -0.2 b-week 4 G1: -1.3 G2: -0.2 Attrition NR Adherence/ compliance NR
Author, Year Kocsis, 2009^4^ Kocsis Country, setting United States Multicenter- REVAMP Study Funding NIMH Research Objective To determine the role of adjunctive psychotherapy in the treatment of chronically depressed patients with less than complete response to an initial medication trial Quality Rating Fair | Study design RCT Type of analysis Completers or per protocol (PP) N 491 Duration Phase I (Medication Algorithm) Only: 12 wks Phase II (Randomization Phase Meds & psychotherapy): 12 wks Primary outcome measure: HAMD and CGI Remission performed biweekly Interventions Antidepressant Only Antidepressant + Brief Supportive Psychotherapy Antidepressant + Cognitive behavioral analysis System of Psychotherapy G1: MEDS Only G2: MEDS + Psychotherapy G3: MEDS + Brief Supportive Psychotherapy G4: MEDS + Cognitive Behavioral Analysis System of Psychotherapy (CBASP) G1: MEDS only G2: MEDS + Psychotherapy G3: BSP G4: CBASP G1: MEDS only G2: MEDS + Psychotherapy G3: BSP G4: CBASP Medications Allowed Next step medication in the following sequence: Sertraline; escitalopram, ibuprorpion, venlafaxine, mirtazapine, and/or lithium augmentation During first 4 weeks, if intolerant moved to next level of sequence Strategy Combination Parameters G1: Meds only G2: Meds + plus either CBASP or BSP G3: Meds + BSP: includes, reflective listening, empathy, evoking affect, therapeutic optimism, and acknowledgment of patients' assets; specific interpresonal, cognitive, behavioral, and psychodynamic interventions were strictly proscribed; Administered for 16 -20 sessions during 12 wks of treatment. G4: Meds + CBASP: structured CBT with a structured interpersonal problem-solving algorithm; Administered twice weekly during weeks 1 - 4 and weekly through wks 5 -12; 16 total sessions. | TRD definition; - For entry into the randomization phase of study pts had to participate in open-label phase of antidepressant algorithm and had to achieve less than remission (remission defined as ≥ 60% reduction in HAMD score, HAMD total score < 8, and no longer meeting DSM-IV criteria for MDD).; - Required failure in current episode; Tier 2 Inclusion criteria; - MDE ≥ 4 wks and depressive symptoms for more than 2 yrs without remission; Diagnosis of double depression, chronic major depression, recurrent depression with incomplete recovery between episodes; 18-75 yo; HAM-D24 score ≥ 20; English speaking; informed consent; understanding of the nature of the study; Exclusion criteria; - Pregnancy; current diagnosis of any psychotic disorder, history of bipolar disorder; dementia; principal diagnosis of PTSD, AN, BN, OCD; antisocial, schizotypal or severe borderline personality disorder; current alcohol or other substance-related dependence requiring detoxification (exception nicotine dependence); previous treatment with cognitive behavioral analysis system of psychotherapy (CBASP) failing at least 4 of the treatment steps in pharmacotherapy algorithm; unwilling to terminate other forms of psychiatric treatment; serious unstable or terminal medical illness | Subgroups Chronic Depression Baseline n G1: 96 G2: 395 G3: 195 G4: 200 Treatment Failure Failed 1 or more, % G1: 100 G2: 100 G3: 100 G4: 100 Polarity, % Unipolar G1: 100 G2: 100 G3: 100 G4: 100 Patient Characteristics Age, mean yrs G1: 43.2 G2: 45.9 G3: 46.4 G4: 45.3 G1: vs. G2: p = 0.05 Sex, % females G1: 49.0 G2: 57.0 G3: 57.9 G4: 56.0 Race, % white G1: 85.4 G2: 89.6 G3: 89.2 G4: 90.0 G1: vs. G2, p = 0.03 Not Specified, % G1: NR G2: NR G3: NR G4: NR Right handed, % G1: NR G2: NR G3: NR G4: NR Groups similar at baseline There were small but statistically significant differences in Race (p = 0.03) and Age (p = 0.05) in the MEDS only vs. MEDS +Psychotherapy comparison. HAM-D 17 Baseline score, mean (SD) G1: 18.37 (8.00) G2: 19.48 (8.27) G3: 19.44 (8.31) G4: 19.52 (8.26) | HAM-D (Insert #) Yes HAMD24 G1: MEDS only G2: MEDS + Psychotherapy G3: BSP G4: CBASP N analyzed Baseline G1: 94 G2: 384 G3: 189 G4: 195 Week 2: G1: 92 G2: 370 G3: 181 G4: 189 Week 4: G1: 85 G2: 359 G3: 176 G4: 183 Week 6: G1: 80 G2: 346 G3: 170 G4: 176 Week 8: G1: 84 G2: 341 G3: 168 G4: 173 Week 10: G1: 79 G2: 333 G3: 163 G4: 170 Week 12: G1: 76 G2: 342 G3: 168 G4: 174 Endpoint score, mean (SD) Week 2: G1: 16.82 (9.21) G2: 17.87 (8.55) G3: 18.14 (8.99) G4: 17.61 (8.13) Week 4: G1: 15.27 (9.46) G2: 17.09 (8.49) G3: 17.24 (8.04) G4: 16.94 (8.92) Week 6: G1: 13.74 (7.97) G2: 15.55 (8.65) G3: 16.28 (8.70) G4: 14.85 (8.57) Week 8: G1: 13.71 (8.54) G2: 14.74 (8.45) G3: 15.08 (8.26) G4: 14.42 (8.65) Week 10: G1: 13.66 (8.52) G2: 14.04 (8.90) G3: 14.94 (9.38) G4: 13.18 (8.36) Week 12: G1: 12.28 (8.44) G2: 12.02 (8.39) G3: 12.77 (8.45) G4: 11.29 (8.30) Change, mean (SD) At 12 weeks, calculated: G1: -6.09 (NR) G2: -7.46 (NR) G3: -6.67 (NR) G4: -8.23 (NR) Responders, n Partial Response Week 2 G1: 6 G2: 33 Week 4 G1: 9 G2: 31 Week 6 G1: 8 G2: 48 Week 8 G1: 9 G2: 51 Week 10 G1: 8 G2: 53 Week 12 G1: 16 G2: 89 Full Response Week 2 G1: 7 G2: 9 Week 4 G1: 10 G2: 22 Week 6 G1: 13 G2: 31 Week 8 G1: 13 G2: 47 Week 10 G1: 13 G2: 57 Week 12 G1: 11 G2: 52 Remitters, n Week 2 G1: 17 G2: 46 G3: 26 G4: 20 Week 4 G1: 24 G2: 50 G3: 21 G4: 29 Week 6 G1: 23 G2: 71 G3: 30 G4: 41 Week 8 G1: 23 G2: 76 G3: 33 G4: 43 Week 10 G1: 21 G2: 89 G3: 39 G4: 50 Week 12 G1: 30 G2: 119 G3: 52 G4: 67 Other Response: Categorical status as remitter, nonresponder or partial responder. Remitter: HAM-D score of < 8 that had decreased by at ≥ 50% from baseline and having a CGI score of 1 or 2 for 2 consecutive visits. Partial responder: havina Ham-d score of 8-16 that had decreased by at ≥ 50% from baseline and having a CGI score of ≤ 3 or HAM-D score of < 8 and CGI of 1 or 2 for 1 wk but not 2 consecutive wks Nonresponder: not meeting criteria of remitter or a partial responder. Mixed-effects linear regression analysis: G1: vs. G2, p = 0.67 G3 vs. G4, p = 0.04 Mixed-effects ordinal logistic regression analyses: G1: vs. G2, p = 0.39 G3 vs. G4, p = 0.06 Treatment × time interaction: G1: vs. G2:, p = 0.03 G3 vs. G4, p = 0.79 HAMD Remission (<8) G1: 30 (31.3) G3: 52 (26.7) G4: 67 (33.5) P = NR QIDS Intervention G1: MEDS only G2: MEDS + Psychotherapy G3: BSP G4: CBASP N analyzed G1: 89 G2: 365 G3: 179 G4: 186 Week 2: G1: 88 G2: 347 G3: 170 G4: 177 Week 4: G1: 81 G2: 351 G3: 171 G4: 180 Week 6: G1: 75 G2: 336 G3: 166 G4: 170 Week 8: G1: 82 G2: 326 G3: 161 G4: 165 Week 10: G1: 77 G2: 323 G3: 154 G4: 169 Week 12: G1: 73 G2: 330 G3: 162 G4: 168 Baseline score, mean (SD) G1: 10.16 (4.50) G2: 10.85 (4.77) G3: 10.89 (4.79) G4: 10.82 (4.76) Endpoint score, mean (SD) Week 2: G1: 9.10 (5.19) G2: 9.90 (4.64) G3: 10.20 (4.88) G4: 9.60 (4.39) Week 4: G1: 8.49 (5.51) G2: 9.27 (4.65) G3: 9.50 (4.65) G4: 9.04 (4.66) Week 6: G1: 7.69 (4.56) G2: 8.81 (4.76) G3: 9.25 (4.97) G4: 8.38 (4.52) Week 8: G1: 7.95 (5.12) G2: 8.27 (4.60) G3: 8.47 (4.59) G4: 8.08 (4.60) Week 10: G1: 7.60 (4.61) G2: 7.62 (4.83) G3: 8.03 (4.89) G4: 7.25 (4.77) Week 12: G1: 7.49 (5.24) G2: 6.96 (4.59) G3: 7.30 (4.41) G4: 6.63 (4.76) Change, mean (SD) Calculated: G1: -2.67 (NR) G2: -3.89 (NR) G3: -3.58 (NR) G4: -4.19 (NR) Other Remission defined as having a total score of 6. Significance NR Remission, #: Week 2 G1: 24 G2: 64 G3: 32 G4: 32 Week 4 G1: 29 G2: 94 G3: 45 G4: 49 Week 6 G1: 27 G2: 93 G3: 43 G4: 50 Week 8 G1: 28 G2: 101 G3: 47 G4: 54 Week 10 G1: 32 G2: 126 G3: 56 G4: 70 Week 12 G1: 32 G2: 152 G3: 67 G4: 85 | Quality of Life Yes Scale Longitudinal Interval Follow-up Evaluation Range of Impaired Functioning Tool (LIFE-RIFT) Intervention G1: MEDS only G2: MEDS + Psychotherapy G3: BSP G4: CBASP Baseline n Baseline G1: 77 G2: 306 G3: 154 G4: 152 Week 4: G1: 81 G2: 342 G3: 171 G4: 171 Week 8: G1: 80 G2: 326 G3: 162 G4: 164 Week 12: G1: 75 G2: 334 G3: 162 G4: 172 Baseline score, mean (SD) G1: 12.64 (3.01) G2: 12.70 (3.05) G3: 12.71 (3.14) G4: 12.69 (2.96) Endpoint score, mean (SD) Week 4: G1: 12.07 (3.54) G2: 11.96 (3.15) G3: 12.13 (3.15) G4: 11.78 (3.14) Week 8: G1: 11.15 (3.33) G2: 11.50 (3.29) G3: 11.76 (3.28) G4: 11.25 (3.30) Week 12: G1: 10.96 (3.63) G2: 10.48 (3.36) G3: 10.73 (3.46) G4: 10.24 (3.25) Change, mean (SD) At wk 12, Calculated: G1: -1.68 G2: -2.22 G3: -1.98 G4: -2.45 Other Mixed-effects linear regression: G1: vs. G2, p = 0.31 G3 vs. G4, p = 0.09 Interaction between treatment and time: G1: vs. G2, p = 0.27 G3 vs. G4, p = 0.52 Scale Intervention Baseline n Baseline score, mean (SD) Endpoint score, mean (SD) Change, mean (SD) Other Adverse Events Overall, % NR Amnesia, % NR Cardiovascular adverse events, % NR Cognitive impairment, % NR Dizziness, % NR Headache, % NR Insomnia, % NR Post op complications, % NR Somnolence, % NR Suicidality, % NR Additional Comments NA Utilized the Frequencey, Intensity and Burden of Side Effects Rating form: Moderate Intensity (% of patients): G1: 17.7 G2: NR G3: 27.0 G4: 26.2 Moderate burden (% of patients): G1: 8.3 G2: NR G3: 11.8 G4: 14.0 Neuropsychological or executive functioning No Measures, Results NR Predefined Yes MMSE No Baseline n Baseline score, mean (SD) Endpoint score, mean (SD) Change, mean (SD) Other Other Yes Utilized the Frequencey, Intensity and Burden of Side Effects Rating form: Moderate Intensity (% of patients): G1: 17.7 G2: NR G3: 27.0 G4: 26.2 Moderate burden (% of patients): G1: 8.3 G2: NR G3: 11.8 G4: 14.0 Adequate information Yes Attrition Overall, % 13.8 At end of treatment, % G1: 16.6 G2: 13.2 G3: 13.8 G4: 12.5 At end of followup, % G1: NA G2: NA G3: NA G4: NA Withdrawals due to efficacy, % G1: 5 (5.2%) G2: 5 (1.3%) G3: 4 (2.1%) G4: 1 (0.5%) Withdrawals due to adverse events, % G1: 2 (2.1%) G2: 3 (0.8%) G3: 1 (0.5%) G4: 2 (1.0%) Other NOTE: Study compares G1: vs. G2 and G3 vs. G4; G3 and G4 make up G2. Adherence/ compliance Adherence Number of Sessions attended: mean (SD, Range) G3: 13.2 (7.0, 0 - 21) G4: 12.6 (6.7, 0 - 19) Association of # of sessions attende and probability of remission: G3: 1.01, p = 0.62) G4: 1.02, p = 0.43)

Evidence Table 3 KQ1 head to head: Tier 3

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Chistyakov et al., 2005^5^ Country, setting Israel, single psychiatry department, inpatients Funding Not reported Research Objective To investigate changes in cortical excitability following ECT in patients with major depression (MD) and to compare therapeutic efficacy of ECT combined with rTMS to that of ECT alone. Quality Rating Fair | Study design RCT Type of analysis Cannot tell type of analysis – all reported patients included N 22 Duration Primary outcome at 3 weeks Interventions G1: ECT+ rTMS G2: ECT + placebo Medications Allowed All antidepressants were tapered and discontinued 1 week before start and no patients received anticonvulsant mood stabilizers Strategy Switch Parameters ECT:; - % receiving bilateral: 100; - Intensity: NR; - Number of sessions (range, mean, SD): 2/wk; rTMS; - Frequency (Hz):1; - Motor threshold (%):110; - Number of trains: NR; - Length of train (seconds): NR; - Inter-train interval: NR; - Pulses per session: 900; - Total number of sessions: 4/wk for 3 weeks; Sham rTMS; - Coil was held perpendicularly to scalp surface.; - Patients received 4 sessions/wk | TRD definition Patients referred for ECT, AD failures were not required. Tier 3 Inclusion criteria; - DSM IV criteria for major depression; - age was between 20 and 75 years; Exclusion criteria; - Suicidal risk; - any central or peripheral nervous system disease,; - seizure disorder,; - history of head trauma in last year,; - systemic uncontrolled disease,; - pacemaker or metallic implants; - drug or alcohol abuse | Treatment Failure Mean failed trials NR Polarity, % 100% MDD Age, mean yrs G1: 59.2 G2: 54.0 Sex, % females G1: NR G2: NR Overall: 68 HAM-D Baseline n G1: 12 G2: 10 Baseline score, mean (SD) Reported in graph only | HAM-D Endpoint score, mean (SD)NR Change, mean (SD) NR Group × time, P > 0.05 Responders, n G1: NR G2: NR Overall: 19 (86%) P = NR (ns) | Quality of Life NR Adverse Events NR Neuropsychological or executive functioning No Measures, Results NR Predefined No MMSE NR Attrition NR Adherence/ compliance NR
Author, Year Hansen, 2010^6^ Hansen Country, setting Denmark University Hospital Inpatient Psychiatric Funding Danish Council for Medical Research; Einar Geert-Jorgensen and Wife Ellen Geert-Jorgensen Research Foundation; Boutcher Worzner and wife Inger Worzner grant; the Aarhus University Foundation for Researhc in Mental Disease; the Foundation of Psychiatric Research Research Objective To compare the antidepressant efficacy and adverse effects of right prefrontal low-frequency rTMS with that of ECT. Quality Rating Fair - KQ1 KQ4? | Study design RCT Type of analysis ITT PP N 60 Duration Active treatment: 3 wks HAMD and UKU assessed at baseline and weekly intervals w/in 24 hrs of treatment Follow-up treatment: 7 wks (total duration) HAMD and UKU assessed at wk 5 and wk 7 Interventions ECT rTMS G1: rTMS G2: ECT Medications Allowed Continued current antidepressant medication; discontinued antiepileptics prescribed as mood stabilizers, benzodiazepines tapered off, low dose zopiclone or zopidem if needed for sleep Strategy Augment or add-on strategy Parameters G1: Location: Right DLPFC Frequency: 1 Hz Intensity: 110% MT Trains: 2 60s trains Intertrain interval: 180 s Number of session: 15 total (1 per week day for 3 weeks) G2: Location: Unilaterally over the right hemisphere Intensity: Recorded seizure duration ≥ 25 seconds; If between 15-25 seconds next treatment carried out with 50% higher stimulus intensity; If < 15 seconds then followed by restimulation. Number of session: 9 total (3 sessions weekly) | TRD definition; - Patients referred for ECT; Tier 3 Inclusion criteria; - 18-80 yo; HAMD-17 total score of ≥ 20 and/or subscale score of ≥ 9; right-handed; ICD-10 diagnosis of moderate to severe depression; DSM-IV diagnosis of MDD; unipolar or bipolar; Exclusion criteria; - Organic brain damage; personal/family history of epileptic seizures, metallic objects in the chest or brain as a result of surgery; cardia pacemakers; somatic diseases associated w/ brain dysfunction; pregnancy; use of coercive measures; suicidal risk of severe degree; severe agitation; delirium; alcohol or drug dependence. | Subgroups No Subgroups Baseline n G1: 30 G2: 30 Treatment Failure Failed 1 or more, % G1: NR G2: NR Failed 2 or more, % G1: NR G2: NR Current episode failures, mean G1: NR G2: NR Mean failed trials G1: NR G2: NR Polarity, % Unipolar G1: 86.7 G2: 86.7 Bipolar I G1: 13.3 G2: 13.3 Bipolar II G1: NR G2: NR Patient Characteristics Age, mean yrs Median (range) G1: 46 (14-38) G2: 52 (29-79) p = 0.16 Sex, % females G1: 76.7 G2: 63.3 Race, % white G1: NR G2: NR Not Specified, % G1: NR G2: NR Right handed, % G1: 100 G2: 100 Groups similar at baseline Yes HAM-D 17 Baseline score, mean (SD) Median (Range): G1: 24 (14-38) G2: 24 (16-34) G1: vs. G2: p = 0.68 | HAM-D (Insert #) Yes HAM-D17 G1: rTMS G2: ECT Endpoint score, mean (SD) Week 3 G1: NR Baseline - wk3 reduction, p <0.001 G2: NR Baseline - wk3 reduction, p <0.001 Week 3-7 G1: NR wk3 - wk7 reduction, p <0.001 G2: NR wk3 - wk7 reduction, p = 0.78 Week 7 G1: NR Baseline - wk 7 reduction, p < 0.001 G2: NR Baseline - wk 7 reduction, p < 0.001 Change, mean (SD) G1: NR G2: NR Responders, n Response Rate Difference Week 3, Rate (95% CI): G1: 0.20 (0.08-0.39) G2: 0.57 (0.37-0.75) G1: vs. G2 rate difference: 0.37 (0.14-0.59), p = 0.003 Week 7, Rate (95%CI): G1: 0.43 (0.25-0.63) G2: 0.60 (0.41-0.77) G1: vs. G2 rate difference: 0.17 (-0.08, 0.42), p = 0.200 Remitters, n Remission Rate Difference Week 3 Rate (95% CI): G1: 0.27 (0.12 - 0.46) G2: 0.53 (0.34 - 0.72) G1: vs. G2 rate difference: 0.26 (0.03 - 0.51), p = 0.035 Week 7 Rate (95% CI): G1: 0.40 (0.23 - 0.59) G2: 0.57 (0.37 - 0.75) G1: vs. G2 rate difference: 0.17 (-0.08, 0.42), p = 0.200 Other Remission: HAMD-17 ≤ 12 Response: ≥ 50% reduction in HAMD-17 | Quality of Life No Adverse Events Overall, % NR Amnesia, % NR Cardiovascular adverse events, % NR Cognitive impairment, % G1: 0 G2: 0 Dizziness, % NR Headache, % NR Insomnia, % NR Post op complications, % NR Somnolence, % Signficantly > decline in fatigue score in the ECT group (score NR) Suicidality, % NR Additional Comments NR “Both treatment forms were generally well tolerated. No serious adverse effects were reported. For 5 patients, rTMS was associated with severe local discomfort or pain, and 4 of them dropped out for that reason. The rest of the rTMS group experienced no or only slight inconvenience. Both groups revealed declining scores during the treatment period. The statistical analyses controlled for several essential variables (data not shown)…None of the 2 methods were associated with cognitive adverse effects or serious adverse effects on the UKU rating scale. Neuropsychological or executive functioning Yes Measures, Results Logical Memory – Immediate recall Baseline, Mean (SD): G1: 10.8 (4.4) G2: 10.0 (5.1) After Treatment G1: 8.8 (3.8) G2: 9.6 (5.1) Logical Memory – Delayed recall Baseline, Mean (SD): G1: 7.6 (5.4) G2: 7.46 (5.5) After Treatment G1: 7.2 (3.7) G2: 6.8 (5.8) Verbal Learning – Total Baseline, Mean (SD) G1: 8.2 (1.7) G2: 8.4 (2.1) After Treatment G1: 8.1 (2.0) G2: 7.9 (1.5) Verbal Learning – delayed recall Baseline, Mean (SD) G1: 5.9 (2.3) G2: 5.5 (2.0) After Treatment G1: 6.0 (2.6) G2: 4.8 (3.1) Rey Complex Figure – copy Baseline, Mean (SD) G1: 32.9 (4.2) G2: 29.7 (7.4) After Treatment G1: 33.6 (2.2) G2: 29.2 (6.8) Rey Complex Figure – delayed recall Baseline, Mean (SD) G1: 16.0 (6.2) G2: 13.9 (7.2) After Treatment G1: 25.6 (7.4) G2: 13.1 (9.4) G1: vs. G2, p <0.01 Within groups, p <0.01 Trail-Making Test A Baseline, Mean (SD) G1: 65.7 (35.5) G2: 64.7 (23.5) After Treatment G1: 60.6 (39.4) G2: 65.9 (34.0) Trail-Making Test B Baseline, Mean (SD) G1: 147.8 (64.4) G2: 131.3 (50.1) After Treatment G1: 131.0 (68.0) G2: 107.8 (36.0) SDMT Baseline, Mean (SD) G1: 29.9 (12.0) G2: 29.3 (13.7) After Treatment G1: 34.0 (12.6) G2: 31.1 (14.0) Verbal Fluency – letter S Baseline, Mean (S) G1: 10.4 (3.8) G2: 11.6 (7.3) After Treatment G1: 12.9 (5.6) G2: 10.3 (6.1) Verbal Fluency – animals Baseline, Mean (SD) G1: 18.4 (6.3) G2: 16.3 (4.5) After Treatment G1: 19.8 (6.2) G2: 14.11 (3.1) G1: vs. G2, p < 0.05 Other Yes “Both treatment forms were generally well tolerated. No serious adverse effects were reported. For 5 patients, rTMS was associated with severe local discomfort or pain, and 4 of them dropped out for that reason. The rest of the rTMS group experienced no or only slight inconvenience. Both groups revealed declining scores during the treatment period. The statistical analyses controlled for several essential variables (data not shown)…None of the 2 methods were associated with cognitive adverse effects or serious adverse effects on the UKU rating scale. Adequate information Yes Attrition Overall, % 30 At end of treatment, % G1: 33.3 G2: 26.7 At end of followup, % G1: NR G2: NR Withdrawals due to efficacy, % G1: NR G2: NR Withdrawals due to adverse events, % G1: NR G2: NR Other Withdrawal due to Discomfort at the stimulus site, % (n): G1: 16.7 (5) G2: 0 (0) Withdrawal due to serious deterioration, % (n): G1: 10 (3) G2: 3 (1) Withdrawal due to somatic disease, % (n): G1: 3 (1) G2: 0 (0) Withdrawal due to Commotio cerebri, % (n): G1: 0 (0) G2: 3 (1) Withdrawal for unknown reasons, % (n): G1: 0 (0) G2: 3 (1) Adherence/ compliance None reported
Author, Year McLoughlin et al., 2007^7^ Eranti et al., 2007^8^ Knapp et al., 2008^9^ Country, setting UK, South London and Maudsley NHS Trust and Pembury Hospital inInvicta Mental Health Trust in Kent, 65.2% were inpatients Funding National Health Service Research and Development, National Coordinating Centre for Health Technology Assessment (NCCHTA) (98/11/04); byGuy's and St. Thomas's Charitable Foundation (R001126); and by a 2003 Ritter Independent Investigator Award from National Alliance for Research on Schizophrenia and Depression. Research Objective To assess clinical effectiveness of rTMS vs. ECT for treating major depressive episodes in patients referred for ECT Quality Rating Good | Study design RCT- pragmatic and single blinded (raters) Type of analysis m-ITT N 46 Duration Primary endpoint at 3 weeks for rTMS and at clinicians discretion for ECT, additional follow-up at 6 months Interventions G1: ECT G2: rTMS Medication Allowed Patients continued their usual medical care and stable psychotropic medications were allowed (i.e. SSRIS, TCAs, Venlafaxine, Mirtazapine, Lithium, Anticonvulsant mood stabilizers, Benzodiazepines, Antipsychotics, Zopiclone, L-Tryptophan) Strategy Augmentation Parameters rTMS; - Frequency (Hz): 10; - Motor threshold (%):110; - Number of trains: 20; - Length of train (seconds): 5; - Inter-train interval: 55; - Pulses per session: 1000; - Total number of sessions:15; ECT:; - % receiving bilateral: 82; - Intensity: 1.5 × ST for bilateral frontotemporal ECT and 2.5 × ST for right unilateral ECT; - Number of sessions (range, mean, SD): range = 2-10, mean = 6.3, SD = 2.5 | TRD definition; - All patients referred for ECT:; - No failure required; Tier 3 Inclusion criteria; - Right handed patients; - more than 18 years old; - refered for ECT due to major depressive episode; Exclusion criteria; - Inability to have rTMS because of metallic implants or foreign bodies; - History of seizures; - Substance misuse in previous 6 months; - Being medically unfit for general anesthesia or ECT:; - ECT or rTMS in previous 6 months,; - Dementia or other axis I diagnosis; - Inability or refusal to provide informed consent. | Treatment Failure Mean failed trials G1: 2.5 (1.4) G2: 2.4 (1.0) Polarity, % MDD G1: 91.67 G2: 90.91 Bipolar G1: 8.33% G2: 9.09 % Age, mean yrs G1: 63.6 G2: 68.3 Sex, % females G1: 67.7 G2: 72.7 Right handed, % Overall: 100% HAM-D 17 Baseline n G1: 22 G2: 24 Baseline score, mean (SD) G1: 24.8 (5.0) G2: 23.9 (7.0) BDI: Baseline score, mean (SD) G1: 36 (8.7) G2: 37.8 (10.5) | HAM-D 17 Analyzed n G1: 22 G2: 23 Endpoint score, mean (SD) End of treatment G1: 10.7 G2: 18.5 P = 0.002, effect size of 1.44 Follow-up at 6 months G1: NR G2: NR P = 0.93 Change, mean (SD) End of treatment G1: -14.1 G2: -5.4 P = 0.017 Responders, n End of treatment G1: 13 (59.1%) G2: 4 (17.4%) P = 0.005 Remitters, n HAM-D ≤ 8 End of treatment G1: 13 (59.1%) G2: 4 (17.4%) P = 0.005 Follow-up at 6 months* G1: 6 (27.4%) G2: 2 (8.7%) *only 12 ECT remitters followed after End of txt BDI Endpoint score, mean (SD) NR P = 0.01 effect size=0.9 Change, mean (SD) NR Group × time, P = 0.25 Responders, n NR Remitters, n NR | Quality of Life SF-36 mental health component score Baseline n G1: 24 G2: 22 Baseline score, mean (SD) G1: 48.9 (12.6) G2: 42.7 (7.5) Other: QALYs Six month QALY gain, mean (SD) G1: 0.0300 (0.053) G2: 0.0297 (0.056) (QALYs were derived using SF-36 data). At six month follow-up, service use data were collected on 28 pts (10-ECT and 18-rTMS). Patients responded much better to ECT than to rTMS by the end of the allocated treatment course. The differential QALY gain of treatment with rTMS over ECT was 0.0003 (p = 0.987). This suggests that treatment by rTMS does not provide any additional gains in quality of life over ECT over a 6-month period. The lack of a statistically significant difference in QALY gain between the two groups may reflect lack of difference in HRSD scores between groups at 6 months. Adverse Events NR Neuropsychological or executive functioning Predefined CAMCOG Attention and orientation subscale (max = 17): ECT baseline 12.8 (3.2), end of treatment 13.9 (3.6), 6mos 13.9 (3.5) rTMS baseline 14.7 (3.0) end of treatment 13.5 (3.3) FU 6 mos 13.4 (3.8), P = 0.004 No significant differences for rest of CAMCOG subscales (verbal fluency, anterograde memory, and retrograde memory) MMSE Baseline score, mean (SD) G1: 24.3 (3.6) G2: 25.7 (3.9) Score at 6 months, mean (SD) G1: 25.4 (5.3) G2: 24.7 (4.8) Endpoint score, mean (SD) G1: 25.6 (3.9) G2: 24.4 (5.3) Change, mean (SD): G1: 1.3 G2: -1.3 P < 0.08 No significant differences on the Columbia ECT Subjective Side Effects Schedule for self-reported cognitive side effects. Attrition Overall to end of treatment 6/46, at 6 months 9/46 At end of treatment, % G1: 6/24 G2: 0 At end of follow-up, % NR Withdrawals due to efficacy, % G1: 5/24 G2: 0 Withdrawals due to adverse events, % 0 Adherence/ compliance NR

Evidence Table 4 KQ1 active versus control: Tier 1

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Avery et al., 2006^10^ Country, setting USA, Single center, University department of psychiatry, outpatient Funding NIMH Research Objective To test hypothesis that patients receiving active TMS would show a greater antidepressant response rate than those receiving sham stimulation Quality Rating Good Fair for KQ2 and subgroups11 (small number of people followed for relapse; used a single measure and did not account for additional medical conditions) | Study design RCT Type of analysis ITT N 68 Duration 4 weeks (15 sessions) of txt, primary assessment 1 week after completion of txts. Responders were evaluated for relapse 2 wks after primary endpoint Interventions G1: High-left TMS G2: Sham Medications Allowed; - Pts encouraged, although not required, to discontinue current antidepressant medication, sedatives, or benzodiazepines; (continuing AD medication G1: 31% vs. G2: 27%; continuing benzodiazapines G1: 26% vs. G2: 24%); - Those stopping medications had to be medication-free for at least 2 weeks; - All responders given AD post rTMS treatment (active or sham); Strategy Mixed-within group differences Parameters rTMS; - Frequency (Hz):10; - Motor threshold (%): 110; - Number of trains: 32; - Length of train (seconds): 5; - Inter-train interval: 25-30; - Pulses per session: 1600; - Total number of sessions: 15 in 4 wks; Sham; - Identical stimulation parameters; - Lateral edgeof coil rotated 90° away from scalp | TRD definition; - Failed to respond to or unable to tolerate at least 2+ adequate AD trials (defined by score ≥3 on ATHF); - Failures not required to be in current episode; Tier 1 Inclusion criteria; - TRD; - 21 to 65 years old; - DSM-IV criteria for current major depressive disorder (MDD); - HAM-D 17 ≥ 17 and a decrease of no more than 20% between screening and 1st txt day; Exclusion criteria; - Previous TMS exposure; - bipolar disorder,; - previous failure of nine or more bitemporal ECT treatments; - current major depressive episode longer than 5 years; - history of substance abuse or dependence withinpast 2 years,; - antisocial or borderline personality disorder,; - active suicidal ideation; - current symptoms of psychosis,; - Hx of seizure disorder,; - Hx of closed head injury with loss of consciousness or prior brain surgery; - any other major psychiatric or medical comorbidity | Subgroups Pain, subgroup analysis presented in Avery et al, 2007^11^ Baseline n G1: 35 G2: 33 Treatment Failure Current episode failures, mean (SD) G1: 1.46 (0.78) G2: 1.48 (0.67) Mean failed trials (SD) G1: 3.2 (2.44) G2: 3.3 (1.72) Polarity, % Unipolar 100 Age, mean yrs G1: 44.3 G2: 44.2 Sex, % females G1: 60 G2: 52 Race, % white NR Right handed, % NR Groups similar at baseline Yes HAM-D 17 Baseline score, mean (SD) G1: 23.5 (3.9) G2: 23.5 (2.9) BDI Baseline score, mean (SD) G1: 28.1 (8.7) G2: 28.4 (8.0) | HAM-D 17 Endpoint score, mean (SD) G1: 15.7 G2: 19.8 Change, mean (SD) G1: -7.8 (7.8) G2: -3.7 (6.3) Group × time P = 0.002 Responders, n G1: 11 (31.4%) G2: 2 (6.1%) P = 0.008 Remitters, n HAM-D21 < 10 G1: 7 (20.0%) G2: 1 (3.0%) P = 0.033 No Relapse (at 6mos), N G1: 5 G2: Unknown (1 relapsed, 1 loss to follow after 3 mos of without relapse) BDI Change, mean (SD) G1: 11.3 (12.8) G2: 4.8 (8.5) Random Regression analyses revealed significant group by time interaction (P = 0.003) | Quality of Life NR Adverse Events Overall, % NR Site pain first session sham none (0/33) vs. TMS group, 41% (14/35)15th session sham 3% (1/30) vs. TMS 33% (11/33). The discomfort pain scale ratings (0-4) decreased inTMS group in subsequent treatment sessions, decreasing from a mean of 1.89 (1.02) at session 1 to 1.11 (1.03) at session 15 (t = 4.24, P < 0.001). Changes from baseline in128 individual SAFTEE scores - emerging symptoms were analyzed by chi-square analyses at visits 5, 10, 15, and 16 with a Bonferroni correction, there were no significant differences between TMS and sham in any ofemerging symptoms. (Data = NR) Neuropsychological or executive functioning No sig differences in GOAT, RAVLT, WAIS-R, COWAT, and SAFTEE; SUBGROUP ANALYSIS11: At 15th session pain TMS 33% vs, sham 3% (P < 0.05) no statistically significant (P > 0.05) time by treatment group interactions for any of neuropsychological test measures. models were refit without interaction term, there was no significant treatment group main effect (P > 0.05) evident for any of neuropsychological tests, indicating groups had similar levels of neuropsychological performance collapsed over time. Several measures showed significant main effects of time, that is, collapsed over groups, there was significant improvement in individual neuropsychological test performances for both groups. No confusion was associated withTMS treatments.GOAT assessments were well within normal range and ranged from 98 to 100. No significant (P > 0.05) differences between groups for any session. MMSE NR Attrition Overall, % 7.4% (5/68) At end of treatment, % NR At end of followup, % NR Withdrawals due to efficacy, % G1: 0 G2: 3.0 Withdrawals due to adverse events, % G1: 0 G2: NR Very unclear as to when patients discontinued Adherence/ compliance NR
Author, Year Bocchio-Chiavetto et al., 2008^12^ Country, setting Italy, Conducted at a single psychiatric unit, patient status NR Funding Ministero dlla Sanita RC 2000 Research Objective To evaluate if rTMS is an effective treatment for TRD Quality Rating Fair | Study design RCT, crossover Type of analysis All reported patients included in the analysis N 36 Duration 5 days of txt (8 week between crossover) Primary endpoint following 1 week of treatment Interventions G1: Overall active G2: Overall sham 5-HTTLPR genotypes G3: LL Active G4: LL Sham G5: S Active G6: S Sham BDNF Val66Met G7: Val/Val Active G8: Val/Val Sham G9: Met Active G10: Met Sham Medications Allowed:; - Patients allowed to continue on typical and atypical psychotics; - 24 patients on mono- or combined therapies with SSRIs; - 12 on other antidepressants (7 on typical, 5 on atypical antipsychotics); - Mean dose as imipramine equivalents = 148.56 ±49.77; Strategy Augmentation Parameters rTMS Low; - Frequency (Hz): 1; - Motor threshold (%): 110; - Number of trains: 40; - Length of train (seconds):10; - Inter-train interval: 20; - Pulses per session: 400; - Total number of sessions: 5 in 5 days; High; - Frequency (Hz):17; - Motor threshold (%):110; - Number of trains: 8; - Length of train (seconds): 3; - Inter-train interval: 120; - Pulses per session: 408; - Total number of sessions: 5 in 5 days; Sham:; - 25mm thick plywood shield, built to appear as an integral part of apparatus, was interposed between the coil itself and scalp, separating the two ones. Ventral surface of coil upside down and stimulus intensity substantially decreased at 60% below motor threshold | TRD definition; - 2+ failures (8+ weeks at standard doses) from 2+ classes of antidepressants; - Required to be in current episode; Tier 1 Inclusion criteria; - HAM-D 21 ≥ 17; - TRD; Exclusion criteria; - Pregnancy, major medical, or neurological disorder | Subgroups Genotypes: 5-HTTLPR (LL or S carriers) BDNF Val66Met (Val/Val or Met carriers) Baseline N G1: 36 G2: 15 G3: 10 G4: 3 G5: 26 G6: 12 G7: 20 G8: 10 G9: 16 G10: 5 Treatment Failure Mean failed trials G1: NR G2: NR G3: 2.80 (0.79) G4: NR G5: 2.92 (1.21) G6: NR G7: 2.79 (0.98) G8: NR G9: 3.00 (1.25) G10: NR Overall: 2.89 Polarity, % MDD G1: 86.1% Bipolar G1: 13.9% Age, mean yrs G1: 59.67 Sex, % females G1: 80.5 Race, % white G1: 100% HAM-D 21 Baseline score, mean (SD) G1: 23.19 (5.12) G2: 24.53 (4.79) G3: 23.40 (6.64) G4: NR G5: 23.12 (4.56) G6: NR G7: 24.10 (5.60) G8: NR G9: 22.06 (4.34) G10: NR | HAM-D 21 Endpoint score, mean (SD) G1: 17.5 (6.91) G2: 21.13 (4.53) 5-HTTLPR G3: 40.49 (25.27) G4: 8.78 (4.23) G5: 19.44 (17.51) G6: 14.11 (16.86) G3 vs G5, P = 0.008 G4 vs G6, P = 0.605 BDNF G7: 32.36 (21.33) G8: 16.52 (10.64) G9: 16.45 (19.90) G10: 6.11 (12.46) G7 vs G9, P = 0.028 G8 vs G10, P = 0.233 Change, mean (SD) G1: -5.69 G2: -3.40 P = NR % Change G1: 25.29% (NR) G2: 13.05% (NR) P = NR | Quality of Life NR Adverse Events NR Neuropsychological or executive functioning No MMSE No Attrition NR Adherence/ compliance NR
Author, Year Boutros et al., 2002^13^ Country, setting US, Yale School of Medicine and VA-Connecticut, outpatient Funding VA Merit Award & K24 DA00520-01A1/DA/NIDA NIH HHS; 1 author employee of Pfizer Research Objective To provide additional data on effiacy and safety for rTMS as an augment strategy in TRD Quality Rating Fair | Study design RCT Type of analysis ITT N 21 Duration 2 weeks txt; follow up with responders for up to 20 weeks post txt Interventions G1: rTMS G2: Sham Medications Allowed Pts allowed to continue all current psychotropic meds Strategy Augmentation, 3 pts in active and 1 in sham txt were not on any meds Parameters rTMS:; - Frequency (Hz):20; - Motor threshold (%): 80; - Number of trains: 20; - Length of train (seconds): 2; - Inter-train interval: 58; - Pulses per session: 800; - Total number of sessions: 10 over 10 weekdays; Sham:; - Coil angled 90 degrees to scalp; - 1 wing of figure 8 touching scalp | TRD definition; - 2+ failed trials of adequate dose and durations; - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - Major Depression; - HAM-D25 >= 20; Exclusion criteria; - Suicidality; - “Prominent” psychotic sympotms; - History of neurological disorders; - current drug abuse | Treatment Failure Mean failed trials NR Polarity, % Unipolar Overall: 100% Age, mean yrs G1: 49.5 G2: 52.0 Sex, % females G1: 25 G2: 10 Right handed, % G1: 90.9 G2: 88.9 HAM-D Baseline n G1: 12 G2: 9 Baseline score, mean (SD) G1: 34.4 (10.1) G2: 31.7 (4.9) | HAM-D Endpoint score, mean (SD) At 2 weeks G1: 29.0 G2: 28.11 Change, mean (SD) G1: -11.75 G2: -6.22 P = NS Responders, n Defined as 30% improvement on HAM-D G1: 7 G2: 2 Responders, n (%) Defined as 50% improvement on HAM-D G1: 3 G2: 2 Relapse Of 6 active treatment responders inluded in20-week follow-up (no continuing intervention), 4 relapsed. Of 1 sham responder included in thh 20-week follow-up, 1 relapsed. | Quality of Life NR Adverse Events Overall, % G1: (% of pts reporting AEs) 66.7 G2: 55.6 Cognitive impairment, % Difficulty concentrating (phase 1 only) G1: 25 G2: NR Headache, % “most frequent complaint” % NR Other:; - scalp tenderness at site of stimulation: 25%, 11.1%; - hearing problem: 8.3%, NR;; - diarrhea: 8.3%, NR; Attrition Overall, % 18.2% (4/22) At end of treatment, % G1: 8.3 (1/12) G2: 30.0 (3/10) At end of followup, % NR Withdrawals due to efficacy, %: NR Withdrawals due to adverse events, %: NR Adherence/ compliance NR
Author, Year Fitzgerald et al., 2006^14^ Country, setting Australia, single center Funding Australian National Health and Medical Research Council and by Constance and Stephen Lieber through a National Alliance for Research on Schizophrenia and Depression Lieber Young Investigator award (to Dr. Fitzgerald) Research Objective rTMS versus placebo for depression Quality Rating Good | Study design RCT Type of analysis ITT (LOCF) N 50 Duration 2 wks double blind with those with >20% decrease in MADRS to continue treatment for up to 6 wks with active or sham txt (LOCF for all pts); sham pts with inadequate response were allowed to enter open label txt. Primary outcome after 2 and 6 weeks of txt Interventions G1: rTMS G2: Sham Medications allowed; - Stable medications allowed; - SSRIs, SNRIs, Tricyclics ADs; - Mood stabilizers,; - Lithium,; - Anticonvulsants,; - Antipsychotic medication,; - Benzodiazepines; Strategy Augmentation, 23% not taking medication at study entry Parameters rTMS Low Right: Frequency (Hz):1; - Motor threshold (%): 110; - Number of trains: 3; - Length of train (seconds): 140; - Inter-train interval: 180; - Pulses per session: 420; Sequential High Left:; - Frequency (Hz): 10; - Motor threshold (%): 100; - Number of trains: 15; - Length of train (seconds): 5; - Inter-train interval: 25; - Pulses per session: 750; - Total number of sessions: 10 sessions/day, 5 days/wk; Sham:; - Coil angled at 45 degrees off head. Medial wing of coil was resting on scalp; - Stimulation parameters identical to those for active treatment (both sides) | TRD definition; - 2+ failed medications with txt duration ≥6 wks; - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - DSM-IV diagnosis of Major Depressive Episode; - MADRS ≥ 20; Exclusion criteria; - Significant medical illness; - Neurological disorders; - Other axis I psychiatric disorders | Treatment Failure Mean failed AD trials (lifetime) G1: 5.6 (3.1) G2: 6.2 (3.0) Polarity, % Unipolar G1: 84% G2: 84% Bipolar G1: 16% G2: 16% Age, mean yrs G1: 46.8 G2: 43.7 Sex, % females G1: 60 G2: 64 HAM-D 17 Baseline n G1: 25 G2: 25 Baseline score, mean (SD) G1: 22.5 (7.4) G2: 19.8 (4.4) BDI Baseline n G1: 25 G2: 25 Baseline score, mean (SD) G1: 29.2 (18.3) G2: 29.3 (9.9) MADRS Baseline n G1: 25 G2: 25 Baseline score, mean (SD) G1: 34.0 (5.9) G2: 34.1 (5.2) | HAM-D 17 Endpoint score, mean (SD) NR Change, % decrease (SD) G1: 45.2% (40.1) G2: 5.4% (23.1) P < 0.001 Change, mean G1: -10.17 G2: -1.07 Responders, n (%) At 6wks G1: 13 (52.0) G2: 2 (8.0) P = 0.001 Remitters, n At 6wks G1: 10 (40.0) G2: 0 (0) P = NR BDI Endpoint score, mean (SD) At week 2 G1: 18.3 (10.3) G2: 221.6 (13.7) At 4 weeks G1: 10.5 (8.3) G2: 21.0 (19.8) At 6 weeks G1: 9.2 (6.7) G2: NR Change, mean (SD) At week 2 G1: 10.9 G2: 7.7 At 4 weeks G1: 18.7 G2: 8.3 At 6 weeks G1: 20.0 G2: NR, P = 0.01 Responders, n NR Remitters, n NR MADRS Endpoint score, mean (SD) At week 2 G1: 26.2 (10.2) G2: 30.9 (8.2) At week 4 G1: 11.7 (7.1 G2: 34.5 (12.0) At week 6 G1: 8.9 (7.9) G2: NA Change, mean (SD) At week 2 G1: 7.8 G2: 3.2 At week 4 G1: 22.3 G2: 0.4 (increased) At week 6 G1: 25.1 G2: NA Group by time, P = 0.001 at all time points Responders, n At 6 weeks G1: 11 G2: 2 P < 0.05 Remitters, n MADRS < 10 At 6 weeks G1: 9 G2: 0 P = 0.005 At week 2 G1: 2 G2: 0 Follow-up at week 3 G1: 3 G2: 0 Follow-up at week 4 | Quality of Life GAF Baseline n G1: 25 G2: 25 Baseline score, mean (SD) G1: 48.8 (8.2) G2: 49.0 (4.9) Endpoint score, mean (SD) G1: 59.0 (16.5) G2: 50.1 (10.3) [P <0.05] Change, mean (SD) G1: 10.2 G2: 1.1 GAF Scale (t=2.0, df=40.2, P < 0.05) Adverse Events Headache, % G1: 20 G2: 8 Nausea 12% vs. 0, No seizures or manic episodes; Hopkins Verbal Learning Test performance decreased for both groups with no group by time interaction. Performance improved ondigit span backward test improved in rTMS only (group by time: P = 0.07). Controlled Oral Word Association test improved for both groups (time: P = 0.001). Nausea 12% vs. 0, No seizures or manic episodes; Neuropsychological or executive functioning Hopkins Verbal Learning Test Performance decreased for both groups with no group by time interaction Digit span backward Test Performance improved in rTMS only (group by time: P = 0.07). Controlled Oral Word Association Test Improved for both groups P = 0.001 MMSE NR Other Nausea 12% vs. 0 No seizures or manic episodes; Attrition Overall, % At 2 weeks: 6 At 3 weeks: 56 At 4 weeks: 70 At 5 weeks: 78 At 6 weeks: 78 After initial 2 weeks, patients that did not have a 10% reduction on a weekly assessment were withdrawn At end of treatment, % G1: 0 G2: 12 At end of follow-up, % G1: 56 G2: 100 Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR Adherence/ compliance NR
Author, Year Fitzgerald et al., 2003^15^ Country, setting Australia 2 general psychiatric services, outpatients Funding National Health and Medical Research Council and a grant fromStanley Medical Research Institute Research Objective To evaluate efficacy of HFL-TMS and LFR-TMS in treatment-resistant depression and compared with a sham-treated control group Quality Rating Good | Study design RCT Type of analysis ITT N 60 Tier 1 Duration Primary endpoint after 2 weeks of txt, after which pts with <20% reduction in MADRS could cross over to the other active txt. Follow-up assessment conducted at 2 weeks post txt. Interventions G1: High Frequency rTMS G2: Low Frequency rTMS G3: Sham Medications Allowed 46 patients continued (failed) AD medication while others were not on a med at study entry. Patients allowed mood stabilizers and antipsychotics Strategy Augmentation Parameters rTMS LowFrequency (Hz):1; - Motor threshold (%): 100; - Number of trains: 60; - Length of train (seconds): 5; - Inter-train interval:60; - Pulses per session: 300; - Total number of sessions: 10 sessions daily, 5 days/week; rTMS High; - Frequency (Hz):10; - Motor threshold (%): 100; - Number of trains: 20; - Length of train (seconds): 5; - Inter-train interval: 25; - Pulses per session: 1000; - Total number of sessions: 10 sessions daily, 5 days/week; Sham rTMS; - Coil angled 45 degrees offhead for 10 sessions daily, 5 days/week | TRD definition; - Failed a minimum of 2 courses of antidepressant medications (6+ weeks); - Not required or not specified to be in current episode; Inclusion criteria; - DSM-IV diagnosis of Major Depression (included bipolar depression); Exclusion criteria; - Significant medical illnesses, neurologic disorders, or other Axis I psychiatric disorders | Treatment Failure Mean failed trials Overall (SD) 5.68 (3.40) Polarity, % Bipolar I G1: 5 G2: 5 G3: 20 Age, mean yrs G1: 42.2 G2: 45.55 G3: 49.15 Sex, % females G1: 40 G2: 35 G3: 55 Right handed, % G1: 90 G2: 100 G3: 85 BDI Baseline n G1: 20 G2: 20 G3: 20 Baseline score, mean (SD) G1: 33.15 (12.12) G2: 35.05 (9.25) G3: 32.30 (9.10) MADRS Baseline n G1: 20 G2: 20 G3: 20 Baseline score, mean (SD) G1: 36.05 (7.55) G2: 37.70 (8.36) G3: 35.75 (8.14) | BDI Endpoint score, mean (SD) At 2 weeks G1: 26.7 (11.9) G2: 27.2 (10.8) G3: 29.0 (8.7) Change, mean (SD) At 2 weeks G1- 6.4 G2: -7.8 G3: -2.3 P = 0.03 MADRS Endpoint score, mean (SD) At 2 weeks G1: 30.8 (7.8) G2: 32.2 (9.0) G3: 35.4 (7.5) Change, mean; % change, (SD) At 2 weeks G1: -5.25; 13.5 % (16.7%) G2: -5.5; 15.0% (14.1%) G3: -0.35; 0.76% (16.2%) P = 0.004 G1: vs. G3, G2 vs. G3, P < 0.005 Responders, n 20% ≤ decrease At 2 weeks G1: 8 (40) G2: 7 (35) G3: 2 (10) P = 0.07 Responders, n 50% ≤ decrease At 2 weeks G1: 0 G2: 1 (5) G3: 0 P = NR CGI Endpoint score, mean (SD) NR P =.01 | Quality of Life GAF Global Assessment of Functioning Baseline n G1: 20 G2: 20 G3: 20 Baseline score, mean (SD) G1: 43.00 (6.76) G2: 43.55 (9.94) G3: 42.75 (7.15) Endpoint score, mean (SD) At 2 weeks G1: 45.2 (7.1) G2: 46.3 (8.5) G3: 42.5 (6.8) Change, mean (SD) At 2 weeks G1: 2.2 G2: 2.85 G3: 0.5 Overall group F56,2=2.6; P =.08; LFR-TMS vs sham: P = 0.03; and HFLTMS vs sham: P = 0.09 Quality of Life Overall group F56,2=2.6; P =.08; LFR-TMS vs sham: P = 0.03; and HFLTMS vs sham: P = 0.09 Adverse Events Dizziness, % G1: 5% G2: 5% G3: 0 G4: 3.3% Other: 0- 2wks:; - 7 (11%) of 60 patients reported site discomfort or pain during rTMS and 6 (10%) reported a headache after rTMS.; - Although there was no difference in incidence of these adverse effects (P =.08), patients inHFL-TMS group seemed to report more discomfort during procedure itself.; - Only 1 patient (HFL-TMS group) reported persistence ofheadache for longer than 1 hour.; - Two patients (1 in each group) reported transient dizziness for a short time after treatment.; 2wks - 4 wks:; - One patient withdrew after 1 session of HFL-TMS treatment insingle-blind phase ofstudy owing to site pain.; - One bipolar patient, who had a successful response to LFR-TMS treatment, experienced a manic episode 10 days after completion of trial after ceasing treatment with valproate sodium; Neuropsychological or executive functioning; - No deterioration in performance was found in any cognitive measures in group as a whole or in analyses of patients who received HFL-TMS only LFR-TMS only, or both active treatment conditions; - Including all patients who underwent at least 1 type of active treatment, there was a significant improvement in performance onverbal paired associates (t50=-7.3; P < 0.001), verbal fluency (t48=-3.8;P < 0.001), and digit span forwards (t48=-1.8; P = 0.003) subscales;Personal Semantic Memory Schedule (t50=-2.4;P = 0.02); andAutobiographical Memory Schedule (t50=-1.9; P = 0.05).; - A similar pattern of improvements was seen for each oftreatment subgroups (HFL-TMS only, LFR-TMS only, or both active treatments).; - Changes in performance oncognitive measures did not correlate with changes in MADRS and Beck Depression Inventory scores acrosssame times.; MMSE NR Other Attrition Overall, % None in initial 2 week treatment phase At end of treatment, % 0 At end of follow-up, % NR But at least 28.3% did not continue on thru2nd 2 weeks Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % G1: 0 (1 during follow-up) G2: 0 (0 during follow-up) G3: 0 (0 during follow-up) Progression of patients through 2nd phase is very unclear Adherence/ compliance NR
Author, Year Garcia-Toro et al., 2001^16^ Country, setting Spain, Inpatient/outpatient status not clearly reported Funding NOTE: CANNOT TELL IF FUNDER IS NON-PROFIT. Association for rehabilitation and social integration of mental patients (ARISPAM) & Madrid community physical handicapped Coordinator Research Objective To clarifyrole played byHF-rTMS applied onleft DLPC as a coadjuvant topharmocological treatment of TRD Quality Rating Fair | Study design RCT Type of analysis Completers N 40 Duration Primary outcome after 2 weeks of treatment. Pts also assessed at 2 weeks follow up post txt Interventions G1: rTMS G2: Sham rTMS Medications allowed; - stable treatment with antidepressants; - most pts taking benzodiazepines; Strategy Augmentation Parameters rTMS; - Frequency (Hz): 20; - Motor threshold (%): 90; - Number of trains: 30; - Length of train (seconds): 2; - Inter-train interval: 20-40; - Pulses per session: 1200; - Total number of sessions: 10 in 10 days; Sham:; - Edge was placed at 90 degrees | TRD definition; - 2+failed trials at maximum tolerated dose for 6+ weeks; - Required to be in current episode; Tier 1 Inclusion criteria; - 18+ years of age; - Unipolar depresssion (DSM IV); Exclusion criteria Previous seizures or neurosurgery, current serious or uncontrolled medical illness, pacemakers, hearing aids, pregnancy or inadequate contraception for females, high suicide risk | Treatment Failure Mean failed trials NR Polarity, % Unipolar 100 Age, mean yrs G1: 51.5 G2: 50.0 Sex, % females G1: 41.2 G2: 44.4 Right handed, % 100 HAM-D 17 Baseline n G1: 20 G2: 20 Baseline score, mean (SD) G1: 27.11 (6.65) G2: 25.6 (4.92) BDI Baseline n G1: 20; Analyzed 17 G2: 20; 18 Baseline score, mean (SD) G1: 27.0 (9.05) G2: 26.38(5.60) CGI-S **CGI subscale not specified inarticle** Baseline score, mean (SD) G1: 476 G2: 4.88 | HAM-D 17 N analyzed G1: 17 G2: 18 Change, mean (SD) At week 1 G1: -4.52(4.66) G2: -2.87(4.27) P = 0.297 At week 2 G1: -7.05 (5.66) G2: -1.77(3.78) P = 0.003 2 week follow up G1: -8.17(7.69) G2: -2.05(6.07) P = 0.013 Responders, n (%) G1: 5 (25) G2: 1 (5) P=NR BDI Endpoint score, mean (SD) NR Change, mean (SD) At 2 weeks G1: -1.35(4.44) G2: -2.75(4.28) P = 0.299 2 week follow up G1: -4.05 (6.72) G2: -1.66(6.89) P = 0.307 CGI-S Change, mean (SD) At week 2 G1: -0.82(0.80) G2: -0.27(0.66) P = 0.04 2 week follow up G1: -1.00(1.17) G2: +0.27(0.95) P = 0.037 | Quality of Life NR Adverse Events NR Additional Comments “most frequency side effects were scalf discomfort and slight and transitory headaches in approximately a third ofcases, nearly all from stimulation group” Neuropsychological or executive functioning No Measures, Results NR Predefined No MMSE NR Adequate information No Attrition Overall, % 12.5 (5/40) At end of treatment, % NR At end of follow up, % G1: 15 G2: 10 Withdrawals due to efficacy, % G1: NR G2: Withdrawals due to adverse events, % G1: NR G2: Other 3 patients in txt group w/drew because of changes in pharmacotherapy, in sham group: 1 “prefered a change in treatment” andother was abusing alcohol and thus removed fromstudy. Adherence/ compliance NR
Author, Year Garcia-Toro et al., 2006^17^ Country, setting Spain, single center, all outpatients Funding Fundacio La Marato de TV3 Research Objective To assess the efficacy of high and low frequency rTMS and different locations of activation Quality Rating Fair | Study design RCT Type of analysis Cannot tell, all reported patients included in analysis N 30 Duration; - Primary outcome after 2 weeks of active treatment; - Follow up: 2 weeks post treatment; Interventions G1: Sham G2: rTMS G3: rTMS + SPECT (focused on different regions of brain after examination with single photon emission computed tomography [SPECT] exam) Medications allowed All pts continued (failed) AD medication and other psychotropic meds Strategy Augmentation Parameters rTMS Low:; - Frequency (Hz):1; - Motor threshold (%): 110; - Number of trains: 30; - Length of train (seconds): 60; - Inter-train interval:; - Pulses per session: 1800; - Total number of sessions: 10 in 2 wks; High; - Frequency (Hz):20; - Motor threshold (%): 110; - Number of trains: 30; - Length of train (seconds): 2; - Inter-train interval: 20+5; - Pulses per session: 1200; - Total number of sessions: 10 in 2 wks; Sham; - Same but with coil angling 45 degrees away from scalp | TRD definition; - Failed 2+ txt trials at 4+ weeks; - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - At least 18 yrs old, MDD, unipolar; Exclusion criteria; - Contraindications for rTMS and high suicide risk | Subgroups None Treatment Failure Mean failed trials NR Polarity, % Unipolar 100% Age, mean yrs G1: 47.2 G2: 48.5 G3: 51.1 Sex, % females G1: 70 G2: 40 G3: 40 Race, % white NR Right handed, % G1: 90% G2: 100% G3: 100% HAM-D 21 Baseline n G1: 10 G2: 10 G3: 10 Baseline score, mean (SD) G1: 25.10 (7.28) G2: 27.30 (4.97) G3: 25.00 (4.14) CGI-S Baseline n G1: 10 G2: 10 G3: 10 Baseline score, mean (SD) G1: 4.7 (0.82) G2: 4.8 (1.0) G3: 4.8 (0.63) | HAM-D 21 Endpoint score, mean (SD) At week 1 G1: 23.6 (7.04) G2: 24.1 (7.91) G3: 21.6 (3.10) At week 2 G1: 23.6 (7.79) G2: 20.10 (8.18) G3: 18.10 (6.15) Follow up 2 weeks post treatment G1: 23.67 (5.55) G2: 20.88 (7.26) G3: 16.9 (7.0) Change, mean (% change) At 1 week G1: -1.5 (-5.9%) G2: -3.2 (-13.27%) G3: -3.4 (-13.6%) At 2 weeks G1: -1.5 (-5.9%) G2: -7.2 (-26.37%) G3: -6.9 (-27.6%) G1: vs. G2+G3 (mean = 7.05), P = 0.048 Follow up at week 4 G1: -1.43 (-5.6%) G2: -6.42 (-23.51%) G3: -8.1 (-32.4%) G1: vs. G2+G3, P = 0.121 Responders, n (%) G1: 0 (0) G2: 2 (20) G3: 2 (20) P = NR CGI-S Endpoint score, mean (SD) At 2 weeks G1: 4.6 (0.97 G2: 3.8 (1.48) G3: 3.9 (0.99) 2 week follow up G1: 4.75 (1.16) G2: 4.00 (1.15) G3: 3.7 (1.57) | Quality of Life NR Adverse Events NR Attrition Overall, % at 2 weeks 0%, during two week follow-up 3 patents withdrew due to changes in pharmacotherapy At end of treatment, % G1: 0 G2: 0 G3: 0 At end of followup, % NR Does not report which group 3 patients came from Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR rTMS+SPECT received active rTMS that was focused on different regions ofbrain after examination with single photon emission computed tomography (20-Hz rTMS to an area of relatively low activity and 1-Hz rTMS to an area showing relatively high activat Adherence/ compliance Compliance all patients completed active 2 week treatment
Author, Year George, 2010^18^ Country, setting United States, outpatient Funding NIMH as the Optimization of TMS for the Treatment of Depression Study Research Objective To test whether daily left prefrontal rTMS safely and effectively treats major depressive disorder Quality Rating Good | Study design RCT Type of analysis mITT (all randomized patient who started at least 1 treatment session) Completer (randomized patients who were treated according ot protocol and had fewer than 4 rescheduled, missed, or partially completed rTMS sessions dueing weeks 2 to 6) Fully Adherent (fewer than 2 rescheduled, missed, or partially complete sessions; must not have been taking prohibited psychiatric medications or illicit drugs; and had no other protocol violations) N Randomized: 199 ITT: 190 Completers: 154 Adherent: 120 Duration Fixed Duration Active Treatment: 3 wks Variable Duration Active Treatment: 3 wks No-treatment lead-in: 2 wks HAM-D assessment performed twice weekly Acute trial terminated when patients met the stable remission criteria. Interventions rTMS Sham G1: rTMS G2: Sham G1: rTMS G2: Sham G1:rTMS G2: Sham Medications Allowed None (2 week washout) Strategy Switch strategy Parameters G1: Location: Left prefrontal cortex Frequency: 10 Hz Intensity 120% MT Pulses: 10 pulses per second for 4 seconds; 3000 persession Intertrain interval: 26 seconds Length of Session: 37.5 minutes (75 trains) Fixed Active Treatment - Number of sessions: daily weekday sessions (15 sessions) Blinded treatment for improvers - Number of sessions: daily weekday sessions for up to another three weeks (total possible sessions = 30) G2: Similar coil as active treatment witha metal insert blocking the magnetic field and scalp electrodes that delivered matched somatosensory sensations. | TRD definition; - Moderate level of treatment resistance as defined by the ATHF; insufficient clinical benefit to 1-4 adequate medication trials or intolerant to ≥ 3 trials; Author personal communication states, “All patients had either one failed antidepressant failure, or multiple intolerance to antidepressant medications.”; - Not required in the current episode; Tier 2 Inclusion criteria; - Antidepressant medication-free outpatients; 18-70 yo; DSM-IV MDD, single or recurrent; HAM-D24 ≥ 20; Stable during 2wk medication-free lead-in; moderate level of treatment resistance as defined by the Antidepressant Treatment History Form (ATHF); insufficient clinical benefit to 1-4 adequate medication trials or intolderant to ≥ 3 trials.; Exclusion criteria; - Other current Axis I disorders; past failure to respond to an adequate trial of ECT; prior treatment with TMS or VNS; personal or close family history or seizure disorder; Neurologic disorder; Ferromagnetic material in body or close to head; pregnancy; taking meds known to lower seizure threshold. | Subgroups No Subgroups Baseline n mITT G1: 92 G2: 98 Treatment Failure Failed 1 or more, % G1: NR G2: NR Failed 2 or more, % G1: NR G2: NR Current episode failures, mean Mean, median (SD) G1: 1.62, 1 (1.37) G2: 1.41, 1 (0.97) Mean failed trials Mean, median (SD) G1: 3.34, 2 (2.68) G2: 3.28, 3 (2.11) Polarity, % Unipolar G1: 100 G2: 100 Bipolar I G1: 0 G2: 0 Bipolar II G1: 0 G2: 0 Patient Characteristics Age, mean yrs G1: 47.7 G2: 46.5 Sex, % females G1: 63 G2: 51 Race, % white G1: NR G2: NR Not Specified, % G1: NR G2: NR Right handed, % G1: NR G2: NR Groups similar at baseline Yes HAM-D 17 Baseline score, mean (SD) G1: 26.3 (5.0) G2: 26.5 (4.8) BDI Baseline score, mean (SD) | HAM-D (Insert #) Yes HAMD24 G1:rTMS G2: Sham N Analyzed mITT G1: 92 G2: 98 Observed: G1: 92 G2: 98 Observed Endpoint: G1: 83 G2: 91 Completers: G1: 72 G2: 82 Fully Adherent: G1: 57 G2: 63 Endpoint score, mean (SD) Observed G1: 21.61 (9.26) G2: 23.38 (7.43) G1: vs. G2, 95% CI Effect Estimate, Cohen d, p-value: -4.23 to 0.10, -0.42, p = 0.06 Change, mean (SD) Observed at 3 weeks G1: -4.65 (NR) G2: -3.13 (NR) Responders, n mITT: G1: 14 G2: 5 p = 0.009 OR of responding to rTMS vs. Sham 4.6 (95%CI, 1.47 to 14.42) Completer: G1: 10 G2: 4 p = 0.02 Fully Adherent: Overall = 7 p = 0.14 Remitters, n No. (95%CI) mITT: G1: 13 (8.5 to 22.7) G2: 5 (2.3 to 11.4) OR (95%CI): 4.18 (1.32 to 13.24) Completers: G1: 10 (7.8 to 23.7) G2: 4 (2.0 to 11.9) OR (95%CI): 4.92 (1.29 to 18.76) Fully Adherent: G1: 6 (5.0 to 21.2) G2: 2 (1.0 to 10.8) OR (95%CI): NS Remitters by Treatment Phase Phase I Fixed(Wks 1-3) G1: 6 G2: 2 Phase I Variable (Wks 4-6) Week 4 Day 2 G1: 2 G2: 0 Week 4 Day 5 G1: 3 G2: 0 Week 5 Day 2 G1: 2 G2: 3 Other Response: ≥ 50% decrease in HAM-D score from baseline) Remission: HAM-D score of 3 or less or 2 consecutive Ham-D scores less than 10 MADRS Yes G1: rTMS G2: Sham Baseline n Observed Baseline G1: 92 G2: 98 Observed End of Phase I G1: 83 G2: 91 Baseline score, mean (SD) G1: 29.5 (6.9) G2: 29.8 (6.4) Endpoint score, mean (SD) Observed at 3 weeks G1: 24.59 (11.44) G2: 27.75 (9.06) G1: vs. G2, 95% CI Effect Estimate, Cohen d, p-value: -6.10 to -0.76, -0.51, p = 0.01 Change, mean (SD) Observed at 3 weeks G1: -4.89 (NR) G2: -2.06 (NR) Responders, n NR Remitters, n NR Other NA IDS Yes G1:rTMS G2: Sham[Q60] Baseline n Observed Baseline: G1: 86 G2: 94 Observed at end of Phase I: G1: 78 G2: 88 Baseline score, mean (SD) G1: 41.0 (9.3) G2: 40.1 (9.8) Endpoint score, mean (SD) Observed at 3 weeks G1: 32.56 (15.40) G2: 36.70 (13.91) G1: vs. G2, 95% CI, Cohen d, p-value: -10.04 to -2.62, -0.66, p = 0.001 Change, mean (SD) Observed at 3 weeks G1: -8.42(NR) G2: -3.37 (NR) Responders, n NR Remitters, n NR Other NA CGI-S Yes G1: rTMS G2: Sham Baseline n Observed at baseline: G1: 90 G2: 98 Observed at end of Phase I: G1: 82 G2: 90 Baseline score, mean (SD) G1: 4.62 (0.70) G2: 4.63 (0.69) Endpoint score, mean (SD) Observed at 3 weeks G1: 3.96 (1.14) G2: 4.30 (0.87) G1: vs. G2, 95% CI Effect Estimate, Cohen d, p-value: -0.68 to -0.09, -0.55, p = 0.01 Change, mean (SD) Observed at 3 weeks G1: -0.66 (NR) G2: -0.33(NR) Other NA | Quality of Life No Adverse Events Overall, % NR Amnesia, % NR Cardiovascular adverse events, % NR Cognitive impairment, % NR Dizziness, % NR Headache, % G1: 32 G2: 23 Insomnia, % G1: 7.6 G2: 10 Post op complications, % NR Somnolence, % G1: 5 G2: 4 Suicidality, % Suicidality: NR Suicides: G1: 0 G2: 0 Additional Comments Those not reported previously below: Discomfort at the stimulation site (%): G1: 18 G2: 10 Worsening depression or anxiety(%): G1: 7 G2: 8 Gastrointestinal(%): G1: 7 G2: 3 Muscle Aches(%): G1: 4 G2: 4 Vertigo(%): G1: 2 G2: 2 Skin Pain(%): G1: 1 G2: 1 Facial Muscle Twitching(%): G1: 0 G2: 1 Other(%): G1: 20 G2: 15 No seizures reported Serious Adverse Events: Syncope (n): G1: 1 patient G2: 0 Paranoid Ideation: G1: 0 G2: 1 patient Neuropsychological or executive functioning No Measures, Results NA Predefined No MMSE No Baseline n Baseline score, mean (SD) Endpoint score, mean (SD) Change, mean (SD) Other Other Yes Those not reported previously below: Discomfort at the stimulation site (%): G1: 18 G2: 10 Worsening depression or anxiety(%): G1: 7 G2: 8 Gastrointestinal(%): G1: 7 G2: 3 Muscle Aches(%): G1: 4 G2: 4 Vertigo(%): G1: 2 G2: 2 Skin Pain(%): G1: 1 G2: 1 Facial Muscle Twitching(%): G1: 0 G2: 1 Other(%): G1: 20 G2: 15 No seizures reported Serious Adverse Events: Syncope (n): G1: 1 patient G2: 0 Paranoid Ideation: G1: 0 G2: 1 patient Adequate information Yes Attrition Overall, % All attrition calculations based on mITT 10.5% At end of treatment, % G1: 12 G2: 9 At end of followup, % G1: NA G2: NA Withdrawals due to efficacy, % G1: NR G2: NR Withdrawals due to adverse events, % G1: 5.4 G2: 0 Other Adherence/ compliance Adherence Fully Adherent n= 120 G1: n = 57 G2: n = 63
Author, Year Holtzheimer et al., 2004^19^ Country, setting USA, single center, outpatient/inpatient status not clearly stated Funding University of Washington Research Objective Initial hypotheses that rTMS would have greater antidepressant effects than sham stimulation and that rTMS would be safe and tolerable Quality Rating Fair | Study design RCT Type of analysis ITT N 15 Duration Primary endoint following 2 weeks of treatment and follow up 1 week after txt completed Interventions G1: rTMS G2: Sham Medications Allowed All pts discontinued (failed) AD medication Strategy Switch Parameters rTMS; - Frequency (Hz): 10; - Motor threshold (%): 110; - Number of trains:32; - Length of train (seconds): 5; - Inter-train interval: 30-60; - Pulses per session: 1600; - Total number of sessions: 10 over 2 wks; Sham rTMS; - Delivered in same anatomical location with identical stimulation parameters, but with lateral edge of coil rotated 45 degrees away from scalp | TRD definition; - Subjects must have failed at least two previous antidepressant trials due to lack of response to an adequate trial (defined by ATHF) or medication intolerance; - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - 21 to 65 years of age; - Right-handed; - Meet DSM-IV criteria for a major depressive episode due to MDD; - HAM-D17 ≥ 18; Exclusion criteria; - No other major psychiatric or medical comorbidity; - History of Bipolar Disorder; - Previous failure of ECT; - History of substance abuse or dependence; - Current symptoms of psychosis; - Pregnancy | Treatment Failure Failed 7 or more, % G1: 85.7 G2: 37.5 Polarity, % Unipolar 100% MDD Age, mean yrs G1: 40.4 G2: 45.4 Sex, % females G1: 57.1 G2: 42.9 Right handed, % G1: 100 G2: 100 HAM-D 17 Baseline n G1: 7 G2: 8 Baseline score, mean (SD) G1: 22.7 (5.3) G2: 20.8 (6.3) BDI Baseline score, mean (SD) G1: 29.6 (10.0) G2: 28.5 (10.6) | HAM-D 17 Endpoint score, mean (SD) At week 1 G1: 18.0 (1.2) G2:18.0 (2.7) At week 2 G1: 14.6 (3.2) G2: 15.3 (3.0) 1 week follow up G1: 18.8 (2.5) G2: 17.6 (2.1) Change, mean (SD) At week 1 G1: 4.7 G2: 2.8 At week 2 G1: 8.1 G2: 5.5 1 week follow up G1: 3.9 G2: 3.2 All endpoints, P = NS Responders, n (%) At week 1 G1: 0 G2: 0 At week 2 G1: 2 (28.6) G2: 1 (12.5) 1 week follow up G1: 0 G2: 0 BDI Endpoint score, mean (SD) At week 1 G1: 27.5 (3.2) G2: 24.9 (2.7) At week 2 G1: 23.9 (2.6) G2: 22.4 (2.4) 1 week follow up G1: 23.9 (1.6) G2: 26.4 (1.9) Change, mean (SD) At 2 weeks G1: 5.7 G2: 6.1 Change, mean (SD) 1 week follow up G1: -5.7 G2: -2.1 Group × time (all points), P = NS | Quality of Life NR Adverse Events No major adverse events at any point in study. Some subjects experienced mild pain withactive rTMS, but treatments were generally well tolerated. Neuropsychological or executive functioning Both groups performed equally well withexception of one measure of verbal memory, Trial 7 ofRey Auditory Verbal Learning Test, in which subjects that received rTMS performed slightly better (rTMS: mean score = 12.7 (2.1) vs.: sham mean score = 12.0 (2.3); P < 0.05). No acute changes in level of consciousness, orientation, or short-term memory associated with any rTMS or sham treatments sessions. MMSE NR There were no major adverse events at any point instudy. Some subjects experienced mild pain withactive rTMS, but treatments were generally well tolerated. Attrition Overall, % 0 during treatment. 3 (20%) beforefinal assessment at week 3 At end of treatment, % 0 At end of followup, % G1: 28.6 G2: 12.5 Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR Other NR Adherence/ compliance Compliance All 15 subjects completed all 10 txt sessions
Author, Year Kauffmann et al., 2004^20^ Country, setting NR, NR – investigators for the US Funding Not reported Research Objective Assessefficacy of right prefrontal slow repetitive rTMS in TRD pts Quality Rating Fair | Study design RCT Type of analysis ITT N 12 Duration 10 treatments over 2 weeks Primary Outcome: Change in HAM-D/Response after 10 sessions Interventions G1: rTMS G2: Sham Medications Allowed allowed to continue antidpressants but advised to discontinue benzodiazepines & mood stablizers Strategy Augmentation Parameters rTMS; - Frequency (Hz):1; - Motor threshold (%): 110; - Number of trains: 2; - Length of train (seconds): 60; - Inter-train interval: 180; - Pulses per session: 120; - Total number of sessions: 10 in 10 days; Sham; - Same as above but coil was held at a 45 degree angle from skull | TRD definition; - 2+ failed AD trials (8+ weeks at adequate doses); - Not required or not specified to be in current episode; Tier 1 Inclusion criteria Major Depression (DSM-IV) age 18+ Exclusion criteria Preexisting neurological and/or cardiac diseases | Treatment Failure Mean failed trials NR: Polarity, % 100% Major Depression Age, mean yrs Overall 51.7 Sex, % females Overall 91.7 HAM-D 21 Baseline n G1: 7 G2: 5 Baseline score, mean (SEM) G1: 21.86 (2.31) G2: 18.20 (2.20) | HAM-D 21 Endpoint score, mean (SEM) G1: 11.29 (3.17) G2: 11.80 (1.93) Change, mean (SD) G1: -10.57 G2: -6.31 P = NR (ns) Responders, n G1: 4 (57%) G2: 2 (40%) Response2, n HAM-D21 <10 G1: 4 (57%) G2: 1 (20%) Relapse On follow up most pts in txt group relapsed after 2-3 month, whereas pts in sham group who improved relapsed in 2 weeks | Quality of Life NR Adverse Events NR Additional Comments There were “No AEs reported” “there were no adverse events” Neuropsychological or executive functioning No Measures, Results NR Predefined Yes MMSE NR Other Yes “there were no adverse events” Adequate information No Attrition Overall, % 0 At end of treatment, % NR At end of followup, % NR Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR Other NR Adherence/ compliance NR NR
Author, Year Padberg et al., 1999^21^ Country, setting Germany, university clinic, patient status not clear Funding Magstim Company Ltd. & Micromed Medizin-Elektronik GmbH Research Objective Compare antridepressant efficacy and tolerability of fast, slow, and sham rTMS in TRD Quality Rating Fair | Study design RCT Type of analysis ITT N 18 Duration 1 week of active txt Primary outcome: Change in HAM-D after 5 txt sessions Interventions B - Repetetive Transcranial Magnetic Stimulation (rTMS)E - Placebo G1: High rTMS G2: Low rTMS G3: Sham rTMS Medication allowed 83.3% of pts continued on their current [failed] AD medication,others were not on a med and did not start one prior to trial Strategy Augmentation Parameters rTMS High; - Frequency (Hz):10; - Motor threshold (%): 90; - Number of trains: 5; - Length of train (seconds): 5; - Inter-train interval: 30; - Pulses per session: 250; - Total number of sessions: 5/wk; rTMS Low; - Frequency (Hz):0.3; - Motor threshold (%): 90; - Number of trains: 10; - Length of train (seconds): 25; - Inter-train interval: NR; - Pulses per session: 75; - Total number of sessions: 5/wk; Sham:; - Same as high rTMS except coil angled at 90 degrees with 1 wing resting on skull | TRD definition; - 2+ failed txt trials of 4+ wks duration including at least one tricyclic; - Required to be in current episode; Tier 1 Inclusion criteria MDD (DSM IV) Exclusion criteria organic brain disorders, contraindications for rTMS | Treatment Failure Current episode failures, mean G1: 4.0 (2.2) G2: 3.2 (0.8) G3: 3.2 (1.2) Polarity, % Unipolar 100 Age, mean yrs G1: 63.5 G2: 46.7 G3: 43.3 Sex, % females G1: 33.3 G2: 83.3 G3: 66.7 Right handed, % G1: 100 G2: 100 G3: 100 HAM-D 21 Baseline n G1: 6 G2: 6 G3: 6 Baseline score, mean (SD) G1: 30.2 (9.5) G2: 26.7 (9.4) G3: 22.2 (8.8) MADRS Baseline n G1: 6 G2: 6 G3: 6 Baseline score, mean (SD) graph only | HAM-D 21 Endpoint score, mean (SD) G1: 28.5 (9.4) G2: 21.5 (21.5) G3: 23.5 (10.4) Change, mean (SD) G1: -1.7 G2: -5.2 G3: -1.3 P > 0.05 Responders, n NR Remitters, n NR MADRS Endpoint score, mean (SD) graph only Group × time, P < 0.1 | Quality of Life NR Adverse Events Headache, % G1: 16.7 G2: 16.7 G3: NR Focal Pain at rTMS site during stimulations: 50%, 33.3%, & 0%. There were no serious AE. Neuropsychological or executive functioning Verbal Memory Tests (included 3 learning trials and a consecutive, delayed recall task after distraction): Verbal memory performance improved significantly after fast rTMS Learning; 1. P = 0.006; 2. NA; 3. Fast rTMS improvement P = 0.032, Slow rTMS P = NS, Sham decrease in performance P = 0.09; MMSE NR Attrition Overall, % NR, “no pts asked for discontinuation of rTMS” At end of treatment, % NR At end of followup, % NR Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR Adherence/ compliance NR - “compliance was excellent”
Author, Year Pallanti et al., 2010^22^ Pallanti Country, setting Italy Single Center Outpatient Funding Italian Department of Health Research Objective Compare unilateral low frequency, sequential bilateral rTMS treatment and sham in pts with TRD under stable pharmacological treatment Quality Rating Fair | Study design RCT Type of analysis Cannot tell N 60 Duration Active treatment: 3 wks Primary outcome measure: HAMD measured weekly Interventions Unilateral rTMS Bilateral rTMS Sham G1: Bilateral Stimulation G2: Unilateral Stimulation G3: Sham Medications Allowed Current [failed] antidepressant regime continued Strategy Augment or add-on strategy Parameters G1: Bilateral: Location of Stimuli: 1st applied of right DLPFC then left DLPFC Right DLPFC Frequency: 3 140s trains at 1 Hz Intensity: 110% RMT Interval: 30s intertrain interval Total 420 stimuli per session Left DLPFC Frequency: 20 5s trains at 10 Hz Intensity: 100% RMT Interval: 25 s intertrain interval Total 1000 styimuli per session G2: Unilateral: Location of Stimuli: Right DLPFC Frequency: 3 140s trains at 1 Hz Intensity: 110% RMT Interval: 30s intertrain interval Total 420 stimuli per session Sham: Left DLPFC Same length of time as the 420 stimuli per session. Carried out with the MAGSTIM placebo coil system. | TRD definition; - Failed two or more adequate (6 weeks or more each) treatments.; - Not required to be in current episode; Tier 1 Inclusion criteria; - Right-handed; ≥ 18 yrs; HAM-D score ≥ 18; ≥ 2 failed AD trials (≥ 6 wk duration); duration ≥ 4mos for current depressive episode; illness duration ≥ 4 yrs.; Exclusion criteria; - Any additional psychiatric comorbidity; rTMS contraindications (metallic implants, foreign bodies, history of seizures); major medical disease; inability or refusal to provide written informed consent. | Subgroups No Subgroups Baseline n G1: 20 G2: 20 G3: 20 Treatment Failure Failed 1 or more, % G1: 100 G2: 100 G3: 100 Failed 2 or more, % G1: 100 G2: 100 G3: 100 Current episode failures, mean G1: NR G2: NR G3: NR Mean failed trials No. of previous adequate courses of medication failed: mean (SD, 95%CI) G1: 5.90 (1.48, 5.21-6.59) G2: 6.50 (1.48, 5.21-6.59) G3: 5.95 (1.67, 5.72-7.28) Polarity, % Unipolar G1: 100 G2: 100 G3: 100 Bipolar I G1: NR G2: NR G3: NR Bipolar II G1: NR G2: NR G3: NR Patient Characteristics Age, mean yrs G1: 47.60 G2: 51.20 G3: 47.85 Sex, % females G1: 55 G2: 60 G3: 60 Race, % white G1: NR G2: NR G3: NR Not Specified, % G1: NR G2: NR G3: NR Right handed, % G1: 100 G2: 100 G3: 100 Groups similar at baseline Yes HAM-D 17 Baseline score, mean (SD) Score (SD, 95%CI) G1: 28.75 (6.01, 25.93-31.57) G2: 27.95 (5.89, 25.19-30.71) G3: 29.05 (3.54, 27.39-30.71) | HAM-D (Insert #) Yes HAM-D17 G1: Bilateral Stimulation G2: Unilateral Stimulation G3: Sham Endpoint score, mean (SD) NR Change, mean (SD) NR Responders, n HAM-D reduction up to 10% G1: 5 G2: 4 G3: 15 χ2 19.17, df 6, Sig. = 0.04 HAM-D reduction up to 25% G1: 5 G2: 6 G3: 3 HAM-D reduction up to 50% G1: 6 G2: 3 G3: 0 HAM-D reduction over 50% G1: 4 G2: 7 G3: 2 NNT (Response) rTMS1 vs. sham 10.00 (95%CI: 3.13 to -8.39) rTMS2 vs. sham 4.00 (95%CI: 2.01 to 328.11) Remitters, n G1: 2 G2: 6 G3: 1 χ2 5.49, df 2, Sig. = 0.064 NNT (Remission) rTMS1 vs. sham 20.00 (95%CI: 4.71 to -8.89) rTMS2 vs. sham 4.00 (95%CI: 2.12 to 36.23) Other Remission: HAM-D < 8 | Quality of Life No Adverse Events Overall, % G1: NR G2: NR G3: NR Amnesia, % G1: NR G2: NR G3: NR Cardiovascular adverse events, % G1: NR G2: NR G3: NR Cognitive impairment, % Week 0 G1: 25 G2: 20 G3: 35 Week 3 G1: 15 G2: 10 G3: 30 Dizziness, % Week 0 G1: 5 G2: 0 G3: 0 Week 3 G1: 0 G2: 0 G3: 0 Headache, % Week 0 G1: 40 G2: 30 G3: 20 Week 3 G1: 5 G2: 5 G3: 5 Insomnia, % G1: NR G2: NR G3: NR Post op complications, % G1: NR G2: NR G3: NR Somnolence, % G1: NR G2: NR G3: NR Suicidality, % G1: NR G2: NR G3: NR Additional Comments Not including previously listed Aes Pain/burning in the scalp: Week 0 G1: 50 G2: 40 G3: 15 Week 3 G1: 5 G2: 0 G3: 10 Anxiety Week 0 G1: 20 G2: 15 G3: 15 Week 3 G1: 0 G2: 0 G3: 5 Seizure Episode Week 0 G1: 0 G2: 0 G3: 0 Week 3 G1: 0 G2: 0 G3: 0 Neuropsychological or executive functioning No Measures, Results NR Predefined Collection method not reported MMSE No Baseline n Baseline score, mean (SD) Endpoint score, mean (SD) Change, mean (SD) Other Other Yes Not including previously listed Aes Pain/burning in the scalp: Week 0 G1: 50 G2: 40 G3: 15 Week 3 G1: 5 G2: 0 G3: 10 Anxiety Week 0 G1: 20 G2: 15 G3: 15 Week 3 G1: 0 G2: 0 G3: 5 Seizure Episode Week 0 G1: 0 G2: 0 G3: 0 Week 3 G1: 0 G2: 0 G3: 0 Adequate information No Attrition Overall, % NR Text states, “none left the study due to pain at the stimulation site” At end of treatment, % G1: NR G2: NR G3: NR At end of followup, % G1: NR G2: NR G3: NR Withdrawals due to efficacy, % G1: NR G2: NR G3: NR Withdrawals due to adverse events, % G1: 0 G2: 0 G3: 0 Text states, “none left the study due to pain at the stimulation site” Other Adherence/ compliance
Author, Year Pascual-Leone et al., 1996^23^ Country, setting Spain, both inpatients and outpatients Funding Generalitat Valenciana andSpanish Minsterio de Educacion y Ciencia Research Objective To study effects of focal rTMS on depressive symptoms of 17 patients with medication-resistant depression of psychotic subtype. Quality Rating Fair | Study design RCT, Cross-over trial Type of analysis ITT N 17 Duration Primary endpoint after 1 week of treatment. Total study duration 5 months (3 week washout between treatments) Interventions B - Repetetive Transcranial Magnetic Stimulation (rTMS)E - Placebo G1: High Freqency rTMS G2: High frequency right rTMS (control) G3: Sham left rTMS G4: Sham right rTMS G5: Real vertex stimulation (control) Medications Allowed Attempts were made to taper medications. Nine patients continued AD medication and only 4 patients were AD free at the end of the study. All pts given nimodipine at a constant dose of 30mg/3× daily Strategy Mixed-within group differences Parameters; - Frequency (Hz):10; - Motor threshold (%): 90; - Number of trains: 20; - Length of train (seconds): 10; - Inter-train interval: 60; - Pulses per session: 2000; - Total number of sessions: 5 in 5days; - Left Sham Coil angeled at 45 degrees with edge of coil resting on scalp; - Right Sham Coil angeled at 45 degrees with edge of coil resting on scalp | TRD definition; - At least three episodes of depression that had been resistant to multiple medications despite combinations and high doses; Tier 1 Inclusion criteria; - Right-handed;; - Diagnosed with major depression, psychotic subtype (DSM-III-R); - history of relapsing unipolar major depression; - Met safety criteria for rTMS; - normal neurological and general physical examinations; Exclusion criteria; - History of bipolar disorder; - History of brain surgery or epilepsy; - Concurrent serious medical illnesses requiring long-term treatment;; - Previously received rTMS | Subgroups Psychosis Treatment Failure Mean failed trials Overal: NR Polarity, % Unipolar Overall: 100 Age, mean yrs Overall: 48.6 Sex, % females Overall: 59% Right handed, % Overall: 100 HAM-D 21 Baseline n Overall: 17(cross-over study, all patients received all interventions) Baseline score, mean (SD) G1: 25.2 G2: NR G3: NR G4: NR G5: NR BDI Baseline score, mean (SD) G1: 47.9 G2: NR G3: NR G4: NR G5: NR | HAM-D 21 Endpoint score, mean (SD) G1: 13.8 G2: NR G3: NR G4: NR G5: NR Change, mean (SD) G1: -11.4 G2: NR G3: NR G4: NR G5: NR P < 0.001 G1: vs. All controls, P < 0.0005 BDI Endpoint score, mean (SD) G1: 25.7 G2: NR G3: NR G4: NR G5: NR Change, mean (SD) G1: -22.2 G2: NR G3: NR G4: NR G5: NR P < 0.0001 G1: vs. All controls, P < 0.0005 | Quality of Life NR Adverse Events Overall, % G1: 41% G2: Amnesia, % G1: NR G2: Cardiovascular adverse events, % G1: NR G2: Cognitive impairment, % G1: NR G2: Dizziness, % G1: NR G2: Headache, % G1: NR G2: Insomnia, % G1: NR G2: Post op complications, % G1: NR G2: Somnolence, % G1: NR G2: Suicidality, % G1: NR G2: Additional Comments Study does not report how A.E.s were reported or elicited. It does state that all pts tolerated rTMS without complications; No seizure induced. Seven pts complained about minor headaches that were not related tostimulation condition. Neuropsychological or executive functioning No Measures, Results NR Predefined No MMSE NR Other Yes Study does not report how A.E.s were reported or elicited. It does state that all pts tolerated rTMS without complications; No seizure induced. Seven pts complained about minor headaches that were not related tostimulation condition. Adequate information No Attrition Overall, % NR At end of treatment, % G1: NR G2: At end of followup, % G1: NR G2: Withdrawals due to efficacy, % G1: NR G2: Withdrawals due to adverse events, % G1: NR G2: Other The authors report, “All patients tolerated rTMS without complications…complications were not related to stimulation condition and did not prompt pts to request discontinuation ofstudy.” Adherence/ compliance NR
Author, Year Rush et al., 2005^24^ Carpenter et al., 2004^25^ Country, setting US, multicenter, outpatient psychiatric Funding Cyberonics, Inc. Research Objective To compare adjunctive VNS to sham in TRD patients Quality Rating Good | Study design RCT Type of analysis m-ITT/PP for efficacy, ITT for Aes N 235 Duration 10wks of stimulation Primary Outcome: HAM-D Response after 10wks txt Interventions G1: VNS G2: Sham Medications allowed pts allowed up to 5 antidepressants, mood stablizers, or other psychotropic medications Strategy Augmentation Parameters VNS: Frequency (Hz): 20 Pulse width (seconds): 500 μs; - On/Off cycle parameters: 30 sec on and 5 min off; - Duration of treatment:; Sham:; - Device implanted but not turned on | TRD definition; - TRD (2-6 failures verified by the ATHF, with failures in tw different drug classes); - Required to be in current episode; Tier 1 Inclusion criteria; - Current Major Depressive Episode (MDE) of 2+ yrs OR 4+ MDE in lifetime,; - age 18-80, HAM-D24>=20;; - bipolar pts had to also be resistant, intolerant of, or have contraindications to lithium; Exclusion criteria; - Atypical or psychotic features in any MDE; - current rapid cycling bipolar disorder, delerium, dementia, amnesia; - other cognitive disoder, suicidality; - risks related to surgical implantation | Treatment Failure Percent with 4-6 current episode failures G1: 46.5% G2: 40.0% Polarity, % Unipolar G1: 88.4 G2: 90.9 Bipolar I G1: 5.4 G2: 3.6 Bipolar II G1: 6.3 G2: 5.5 Age, mean yrs G1: 47.0 G2: 45.9 Sex, % females G1: 59 G2: 66 Race, % white G1: 97 G2: 96 HAM-D24 Baseline n G1: 119 G2: 116 Baseline score, mean (SD) G1: 28.8(5.3) G2: 29.7(5.2) MADRS Baseline score, mean (SD) G1: 31.4(6.3) G2: 31.9(6.3) IDS Baseline n G1: 112 (115 randomized) G2: 110 Baseline score, mean (SD) G1: 44.3(9.1) G2: 45.4(8.5) CGI-I Baseline n G1: 112 G2: 110 | HAM-D24 N analyzed G1: 112 G2: 110 Endpoint score, mean (SD) NR % change, mean (SD) G1: -16.3 (28.1) G2: -15.3 (25.5) P = 0.639 Responders, n G1: 17 (15.2%) G2: 11 (10.0%) P = 0.251 MADRS Endpoint score, mean (SD) NR % change, mean (SD) G1: -17.1 (31.2) G2: -12.4 (27.1) P = 0.208 Responders, n G1: 17 (15.2) G2: 12 (0.0) P = 0.378 IDS Endpoint score, mean (SD) NR % change, mean (SD) G1: 21.2 (25.4) G2: 16.3 (26.2) P = 0.158 Responders, n G1: 19 (17) G2: 8 (7.3) P = 0.032 Remitters, n NR CGI-I Endpoint score, mean (SD) NR Achieving 1 or 2 score, %(SD) G1: 13.9 G2: 11.8 VNS v. Sham, P = 0.648 | Quality of Life Medical Outcomes Study Short Form-36 (MOS-SF36) Baseline n G1: 112/ N=107 QOL analysis G2: 110/ N=107 QOL analysis Baseline score, mean (SD) NR Endpoint score, mean (SD) NR Change, mean (SD) G1: physical component: -0.9 (8.3); mental component: 5.0 (11.6) G2: physical component - 1.6(8.4); mental component: 4.0(10.2) Other Physical component between VNS and sham: P = 0.480, Mental Component between VNS and sham: P = 0.406 Adverse Events Overall, % NR Cardiovascular adverse events, % G1: 5, palpitations 5 G2: 3 Other:–; - voice alteration: 68% v 38%; - cough increased: 29% v 9%; - dyspnea: 23% v 14%,; - dysphagia: 21% v 11%,; - neck pain: 21% v 10%,; - paresthesia: 16% v 10%,; - vomiting: 11% vs. 12%,; - laryngismus 11% v 2%,; - dyspepsia 10 v 5; - wound infection 8% v 2%,; - hypomania/mania (via Young Mania Scale): 1.7% (1pt with a prestudy dx of bipolar) v 0%; Overall SAEs 30, pts VNS: 13.4% (16/119). Sham: 12.1% (14/116) 12 events, involving 11 patients, were cases of worsening depression requiring hospitalization Cardiac SAEs during implantation: 1.7% v 0% COSTART used to code reported events Attrition Overall, % 1.3 (3/235) At end of treatment, % G1: 2.6 G2: 0 At end of follow-up, % NR Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % G1: 2.6 G2: 0 9 pts had a protocol violation post randomization Adherence/ compliance NR
Author, Year Su et al., 2005^26^ Country, setting Taiwan, NS Funding Taipei Veterans General Hospital, patient status not reported Research Objective To investigate whether two weeks of rTMS applied toLDLPFC can alleviate TRD Quality Rating Fair | Study design RCT Type of analysis Completers N 33 Duration 2wk of active txt Primary outcome: HAM-D at 2 weeks (after 10 txt) Interventions B - Repetetive Transcranial Magnetic Stimulation (rTMS)E - Placebo G1: 20Hz rTMS (N analyzed = 10) G2: 5Hz rTMS (N analyzed = 10) G3: Sham (N analyzed = 10) Medications allowed pts allowed to continue all meds constant for 4 weeks prior (e.g. antidepressants, antipsychotics, mood stablizers, or stimulant Strategy Augmentation Parameters rTMS High:; - Frequency (Hz): 20; - Motor threshold (%): 100; - Number of trains:40; - Length of train (seconds):2; - Inter-train interval:28; - Pulses per session: 1600; - Total number of sessions: 5/wk or 10 in 10 weekdays; rTMS Low:; - Frequency (Hz): 5; - Motor threshold (%): 100; - Number of trains: 40; - Length of train (seconds): 8; - Inter-train interval: 22; - Pulses per session: 1600; - Total number of sessions:5/wk or 10 in 10 days; Sham:; - Same as high frequency rTMS. Coil placed at 90 degrees off skull. | TRD definition; - TRD (2+ failed adequate trials); - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - Major Depressive Episode or Bipolar (DSV-IV),; - Ham-D21 score >=18; Exclusion criteria; - history of - epilepsy,; - any physical and neurological abnormalities, major head trauma,; - psychotic symptoms;; - current us of a pacemaker,; - suicidality | Subgroups Ethnicity - Chineese, females by menopausal status Treatment Failure Mean failed trials NR Polarity, % Unipolar G1: 90 G2: 80 G3: 80 Bipolar G1: 10 G2: 20 G3: 20 Bipolar II G1: 10 G2: 10 G3: 10 Age, mean yrs G1: 43.6 G2: 43.2 G3: 42.6 Sex, % females G1: 70 G2: 80 G3: 70 HAM-D 17 Baseline N G1: 10 G2: 12 G3: 11 Baseline score, mean (SD) G1: 23.2 (7.5) G2: 26.5 (5.2) G3: 22.7 (4.7) BDI Baseline score, mean (SD) G1: 28.0(9.1) G2: 33.9(7.6) G3: 33.4(9.6) CGI-S Baseline score, mean (SD) G1: 4.5(0.7) G2: 4.7(0.8) G3: 4.7(0.48) | HAM-D 21 N analyzed G1: 10 G2: 10 G3: 10 Endpoint score, mean (SD) At 2 weeks G1: 12.8(6.7) G2: 12.3(7.7) G3: 19.0(7.7) Change, mean (SD) At 2 weeks G1: -13.4(4.9) G2: -14.2(6.0) G3: -3.7(9.3) G1: vs. G3, G2 vs. G3 P < 0.01 Responders, n G1: 6 (60) G2: 6 (60) G3: 1 (10) G1: + G2 vs. G3 P = 0.01 Remitters, n Ham-D17<= 7 G1: 5 (50) G2: 5 (50) G3: 0 BDI Endpoint score, mean (SD) At 2 weeks G1: 12.8(6.7) G2: 19.7(12.3) G3: 28.7(15.1) Change, mean (SD) At 2 weeks G1: 15.2(7.5) G2: 14.2(10.4) G3: 4.7(9.1) G1: vs. G3 P <0.05 G2 vs. G3 P <0.1 CGI-S Endpoint score, mean (SD) At week 2 G1: 2.8(1.1) G2: 2.0(0.9) G3: 3.6(1.1) Change, mean (SD) G1: -1.7 G2: -2.0 G3: -1.1 P = NS | Quality of Life NR Adverse Events Headache, % G1: 20 (n=2) G2: 20 (N=2) G3: 11.1 (N=1) Pain at rTMS site: 16.7% withdrew due to pain at stimulation site SEE AE section Attrition Overall, % 9.1 (3/33) At end of treatment, % G1: 0 G2: 16.7 G3: 9.1 At end of follow-up, % NR Withdrawals due to efficacy, % G1: 0 G2: 0 G3: 9.1 Withdrawals due to adverse events, % G1: 0 G2: 16.7 G3: 0 1 dropped out of sham for worsening of clinical symptoms, this was categorized as LOE Adherence/ compliance NR
Author, Year Zheng et al., 2010^27^ Country, setting China, Single Center, inpatient/outpatient setting not clearly reported Funding National Natural Science Foundation of China (30830046 to Lingjiang Li), the National Science and Technology Program of China (2007BAI17B02 to Lingjiang Li), the National 973 Program of China (2009CB918303, 2007CB512308 to Lingjiang Li and Zhang Zhijun); Program of Chinese Ministry of Education (20090162110011 to Lingjiang Li);NationalHi-Tech Research and Development Program of China (863 program: 2008AA02Z413 to Zhang Zhijun) Research Objective To assess metabolic changes within prefrontal cortex after rTMS treatment Quality Rating Fair | Study design RCT Type of analysis Cannot tell N 34 Duration 4 weeks Interventions G1: rTMS G2: Sham Medications Allowed Augment – all patients taking escitalopram from 2+ weeks before trial Strategy Augment or add-on strategy Parameters rTMS - 20 sessions of rTMS over the left DLPFC within four weeks, at 110% stimulation intensity related to resting motor threshold | TRD definition; - failure to respond to at least two different antidepressants given for a period longer than 4 weeks at the maximum recommended dose.; - Not required to be in current episode; Tier -1 Inclusion criteria; - Fulfilling the diagnostic criteria for major depressive episode (DSM-IV) and referred for rTMS because of drugtreatment resistance were enrolled in this study.; - Age of the patients was from 18 to 37 years; Exclusion criteria; - Any other psychiatric axis-I or axis-II disorders; - History of epileptic seizures or any other neurological disorder; - Any kind of metal implants; - Any other clinically relevant abnormalities in their medical history or laboratory examinations; - Medical history of alcohol or drug abuse | Subgroups Young adults (18-37) Baseline n G1: 19 G2: 15 Treatment Failure Failed 1 or more, % 100 Failed 2 or more, % 100 Current episode failures, mean NR Mean failed trials NR Polarity, % Unipolar 100 Patient Characteristics Age, mean yrs G1: 26.9 G2: 26.7 Sex, % females G1: 36.8 G2: 33.3 Race, % white NR Not Specified, % NR Right handed, % NR Groups similar at baseline Yes HAM-D 17 Baseline score, mean (SD) G1: 24.6 (3.0) G2: 24.6 (2.8) BDI Baseline score, mean (SD) G1: 21.1 (4.2) G2: 21.0 (4.2) | HAM-D (17) Endpoint score, mean (SD) G1: 13.5 (5.1) G2: 22.9 (3.4) Change, mean (SD) G1: -11.1 G2: -1.7 P = NR Responders, n G1: 12 G2: 1 Remitters, n NR Other Responders - Fisher's exact test, P < 0.001 BDI Yes G1: rTMS G2: Sham Endpoint score, mean (SD) G1: 13.5 (5.1) G2: 19.8 (5.1) Change, mean (SD) G1: -7.6 G2: -1.2 Responders, n NR Remitters, n NR | Quality of Life NR Adverse Events NR Neuropsychological or executive functioning NR MMSE NR Other NR Attrition NR Adherence/ compliance NR

Evidence Table 5 KQ1 active versus control: Tier 2

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Berman et al., 2000^28^ Country, setting US, urban community health center, inpatient and outpatients Funding Veterans Administration, NIMH, State of CT Research Objective To assessefficacy of rTMS in unmedicated TRD patients Quality Rating Fair | Study design RCT Type of analysis ITT N 20 Duration 2 weeks (10 weekdays of txt) Primary outcome = HAM-D at 2wks Interventions G1: rTMS G2: Sham TMS Medications Allowed All patients free of antidepressants, neuroleptics, and benzodiazepines Inpatients pts allowed chloral hydrate for sleep Strategy Switch Parameters rTMS –; - Frequency (Hz): 20; - Motor threshold (%): 80; - Number of trains: 20; - Length of train (seconds): 2; - Inter-train interval:58; - Pulses per session:800; - Total number of sessions: 10 in 10 days; Sham; - Paddle angled approximately 30 – 45 degrees off of scalp with bottom coil margin elevated approximately one-half cm from scalp and lucite paddle casing firmly applied against the scalp | TRD definition; - 1+ failed trials (4+ weeks duration with at least 200 mg mg/d of imiprimine, 20mg/day fluoxetine, 60mg/d phenelzine, 225mg/d venlafaxine, 30mg/d mirtazapine); - Not required to be in current episode; Tier 2 Inclusion criteria; - Current Major depressive episode (via Ham-D); Exclusion criteria; - Hx of sig. neurological illness; - EEG abnormalities suggestive of an epileptic predisposition; - Substance or alcohol use abuse diagnosis,; - Sig. unstable medical illness,; - Females - pregnancy or inadequate birth control | Treatment Failure Current episode failures, mean G1: 5 G2: 3.5 (+ a median of 1 aumgmentation in eachgroup) Polarity, % Unipolar G1: 100 G2: 90 Bipolar II G1: 0 G2: 10 Age, mean yrs G1: 45.2 G2: 39.4 Sex, % females G1: 20 G2: 40 Race, % white G1: 100 (n=1 hispanic) G2: 100 (n=1 hispanic) HAM-D 25 Baseline n G1: 10 G2: 10 Baseline score, mean (SD) G1: 37.1 G2: 37.3 | HAM-D 25 G1: rTMS G2: Sham TMS Endpoint score, mean (SD) At week 2 G1: 24.6 G2: 36.4 *Adjusted Change (based on best fit slopes), mean (SEM) G1: -14.0 (3.7) G2: -0.2 (4.1) P < 0.01 Responders, n 50% decrease from baseline and score <= 15 G1: 1 (10) G2: 0 P = 0.09 Three partial responders symptom severity returned to baseline within 1-2 weeks BDI Change, mean (SD) G1: 11.4 (5) G2: 4.7 (6) P = 0.27 | Quality of Life NR Adverse Events Headache, n G1: 60 G2: 50 Difficulty starting urination great in active group P = 0.03 Remaining 21 potential side effects assessed by the SECL were not significantly different between groups after correction for multiple comparisons (data NR) Poor memory, nausea or vomiting, constipation, drowsiness, blurred vision, increased appetite, dry mouth, decreased appétit, tremors and shakiness, nightmares, difficulty sitting still, trouble concentrating, irregular or pounding heartbeat, diarrhea, frequent need to urinate, rash, ringing in the ears, sweating, faintness or lightheadedness, poor coordination, and muscle stiffness MMSE NR Attrition Overall, % 15 At end of treatment, % G1: 0.0 G2: 30.0 At end of follow-up, % G1: NA G2: NA Withdrawals due to efficacy, % G1: 0 G2: 30 Withdrawals due to adverse events, % G1: 0 G2: 0 Adherence/ compliance NR
Author, Year Manes et al., 2001^29^ Includes additional neuro-psychological outcomes reported in Moser et al., 2002^30^ Country, setting US, outpatient clinic Funding NIMH Research Objective To examineantidepressant efficacy of rTMS in a TRD population Quality Rating Fair | Study design RCT Type of analysis cannot tell if ITT N 20 Duration 2 weeks (1 week of treatment, 1 wk follow-up following last treatment) Primary outcomes HAM-D at end of treatment and at 1 week follow-up Interventions G1: rTMS (N=10) G2: Sham rTMS (N=10) Medications allowed No antidepressant medication Strategy Switch Parameters rTMS; - Frequency (Hz):20; - Motor threshold (%): 80; - Number of trains: 20; - Length of train (seconds): 2; - Inter-train interval: 60; - Pulses per session: 800; - Total number of sessions: 5/wk; Sham:; - Same stimulation, figure 8 coil was above top of skull and handle was placed against head | TRD definition; - Not required or not specified to be in current episode; Setting(s) Outpatient Psychiatric Inclusion criteria; - Major/Minor Depression (DSM IV),; - TRD (1+ failed trial); Exclusion criteria NR | Subgroups Age 50+ Treatment Failure Mean failed trials G1: 4 (2.3) G2: 4 (1.2) Polarity, % Major Depression G1: 80 G2: 100 Dysthymia G1: 20 G2: 0 Age, mean yrs G1: 60.5 G2: 60.9 Sex, % females G1: 50 G2: 50 Race, % white G1: 100 G2: 100 HAM-D Baseline n G1: 10 G2: 10 Baseline score, mean (SD) G1: 22.7 (5.2) G2: 22.7 (7.1) | HAM-D Endpoint score, mean (SD) At 1 week G1: 13.7 (5.4) G2: 16.2 (8.5) 1 week Follow-up G1: 14.4 (6.4) G2: 15.5 (9.1) Change, mean (SD) At week 1 G1: -9 G2: -6.5 1 week follow-up G1: -8.3 G2: -7.2 All time points P >0.66; pts with MDD only - P = 0.3919 Responders, n (%) G1: 3 (30) G2: 3 (30) P = NS Remitters, n G1: 2 G2: 2 P = NR | Quality of Life NR Adverse Events Headache, % G1: 40% G2: 0% Other: Local pain/local discomfort: 10%/40% vs. 0%/40%; anxiety: 0 vs 10% Neuropsychological or executive functioning **30 (endpoint: mean of 3 days after 5 days of txt) Trail Making Test B score Baseline: rTMS: 87.22 Sham: 103.67 Follow-up rTMS: 58.59 Sham: 100.64 **some variation in pts included in two samples but reported as same study by authors. #1564 includes at least 1 participant <50 years old, n=19 Other neuropsychological tests showing no statistical significance in either group: Trail Making Test-A, Stroop Test, WAIS-R digit symbol, Controlled Oral Word Association, Boston naming test, stentance repitition, Rey Auditory Verbal Learning test, & Judgement of Line Orientation MMSE Baseline n G1: 10 G2: 10 Baseline score, mean (SD) G1: 28.7 (1.4) G2: 28.6 (1.3) Endpoint score, mean (SD) At Week 1 G1: 29.6(0.7)) G2: 29.3 (0.7) At Follow-up Week 1 G1: 29.6(1.8) G2: 29.2 (0.8) Change, mean (SD) NR; 1. P >0.41; 2. P = NA; 3. P = NR; Attrition NR Adherence/ compliance NR
Author, Year O'Reardon, 2007^31^ Country, setting US, Canada, Australia; multicenter, outpatient/inpatient status not clearly reported Funding Neuronetics Research Objective To test whether transcranial magnetic stimulation (TMS) overleft dorsolateral perfrontal cortex is effective and safe inacute treatment of major depression Quality Rating Good | Study design RCT Type of analysis Modified ITT (m-itt) N 325 randomized Duration 6 weeks; Primary efficacy outcome (MADRS) collected at wk4. Sham patients could cross over aftr 4 weeks if not responding. Interventions G1: Active TMS G2: Sham TMS Medications Allowed All patients were free of ADs and other psychotropic medications directed at treating depression. Pts allowed only limited use of hypnotics, anxiolytics for txt emergent insomnia or anxiety Strategy Switch Parameters rTMS; - Frequency (Hz): 10; - Motor threshold (%): 120; - Number of trains: 75; - Length of train (seconds): 4; - Inter-train interval: 26; - Pulses per session: 3000; - Total number of sessions: 5/week for 4-6 wks; rTMS Sham:; - Coil has embedded magnetic shield, limiting magnetic energy reaching cortex to 10% or less than active coil | TRD definition; - Specifically required to have failed at least one in this or most recent episode OR four failed attempts in a lifetime; Tier 2 Setting(s) Not clearly reported Inclusion criteria; - Aged 18—70; - DSM-IV diagnosis of MDD; - Single episode or recurrent, with a current episode duration ≤3; - CGI-S score ≥ 4; - HAM-D17 ≥ 20; Symptom stability during a 1-week no-treatment lead-in period, with a HAM-D17 total score of at least 18 and a decrease in score of 25% or less from that observed atscreening assessment Exclusion criteria; - A lifetime history of psychosis, bipolar disorder, or obsessive– compulsive disorder; - Posttraumatic stress disorder and eating disorders (if present in past year); - Lack of response to an adequate trial of electroconvulsive therapy (ECT); - Prior treatment with TMS or a vagus nerve stimulator implant; - Pregnancy; - Personal or close family history of seizure disorder; - Presence of neurologic disorder or medication therapy known to alter seizure threshold; - Presence of ferromagnetic material in or in close proximity to head | Baseline N G1: 165 G2: 160 Current episode failures, meanG1: 1.6 G2: 1.6 Mean failed trials NR Previous treatment, not specified, % NR Polarity, % Unipolar 100 Age, mean yrs G1: 47.9 G2: 48.7 Sex, % females G1: 55.5% G2: 50.7% Race, % white G1: 94.2% G2: 89.7% HAM-D 17 Baseline score, mean (SD) G1: 22.6 (3.3) G2: 22.9 (3.5) MADRS Baseline n G1: 155 G2: 146 Baseline score, mean (SD) G1: 32.8 (6.0) G2: 33.9 (5.7) IDS Baseline n G1: 155 G2: 146 Baseline score, mean (SD) G1: 42.0 (9.4) G2: 43.4 (9.9) CGI-S Baseline n G1: 155 G2: 146 Baseline score, mean (SD) G1: 4.7 (.6) G2: 4.7 (.7) | HAM-D 17 Analyzed n G1: 155 G2: 146 Endpoint score, mean (SD) At week 4 G1: 17.4 (6.5) G2: 19.4 (6.5 At week 6 G1: 17.1 (7.7) G2: 19.6 (7.0) Change, mean (SD) At week 2 G1: -5.2 G2: -3.5 At week 6 G1: -5.5 G2: -3.3 P = 0.005 Responders, n (%) At week 2 G1: 18 (11.6) G2: 13 (8.9) P > 0.10 At week 4 G1: 32 (20.6) G2: 17 (11.5) P < 0.05 At week 6 G1: 38 (24.5) G2: 20 (13.7) P < 0.05 Remission rate n (%) HAM-D17 < 8 At week 2 G1: 5 (3.2) G2: 3 (2.1) P > 0.10 At week 4 G1: 110 (7.1) G2: 9 (6.2) P > 0.10 At week 6 G1: 24 (15.5) G2: 13 (8.9) P = 0.065 MADRS Endpoint score, mean (SD) At 4 weeks G1: 27 (11.1) G2: 29.8 (10.1) At 6 weeks G1: 26.8 (12.8) G2: 30 (10.8) Change, mean (SD) At 4 weeks G1: 5.8 G2: 4.1 At 6 weeks G1: 6 G2: 3.9 Response rate, % At week 2 G1: 8.4 G2: 6.2 P > 0.10 At week 4 G1: 18.1 G2: 11.0 P <0.05 At week 6 G1: 23.9 G2: 12.3 P <0.01 Remission rate, % Remission defined as total score <10 At week 2 G1: 3.9 G2: 2.1 P > 0.10 At week 4 G1: 7.1 G2: 6.2 P > 0.10 At week 6 G1: 14.2 G2: 5.5 P < 0.05 | Quality of Life NR Adverse Events Serious adverse events G1: 6 G2: 5 Suicidality, % G1: 0.6 G 2: 1.9; - Exacerbation of depression: active TMS = 0.6%, sham TMS = 1.9%; - Eye pain: active TMS = 6.1% sham TMS = 1.9%;; - GI disorders toothache: active TMS = 7.3%, sham TMS = 0.6%;; - Application site discomfort: TMS = 10.9%, sham = 1.3%; - Application site pain, %: TMS = 35.8, sham = 3.8; - Facial pain: active TMS = 6.7%, sham TMS = 3.2; - Muscle twitching: TMS = 20.6%, sham = 3.2%; - Pain of skin: TMS = 8.5%, TMS = 0.6%; MMSE NR Attrition Overall, % 15 At end of treatment, % G1: wk2 6%/ wk 4 5% G2: wk 2 9%/ wk 4 6% At end of follow-up, % G1: NR G2: NR Withdrawals due to efficacy, % G1: 0.6% G2: 1% Withdrawals due to adverse events, % G1: 5% G2: 4% Other; - 325 subjects were randomized; - 24 were “nonevaluable”; - 301 continued to receive at least 1 treatment, these 301 were included in final analysis; - 277 completed study through week 4.; Adherence/ compliance NR
Author, Year Stern et al., 2007^32^ Country, setting NR, outpatient setting Funding The Milton Fund, NARSAD,Stanley Vada NAMI Foundation, NIMH, Spanish Ministerio de Educacion y Cienca Research Objective To testhypothesis that rTMS exerts antidepressant effects either by enhancing left dorsolateral prefrontal cortex (DLPFC) excitability (using high-frequency rTMS) or by decreasing right DLPFC excitability (using low-frequency rTMS) have equivalent an Quality Rating Fair | Study design RCT Type of analysis Cannot tell, all reported patients included in the analysis N 45 Duration; - 10 days (2 wk) stimulation and 2 wk f/u for all 4 gps; - An additional 2 wk of unblinded f/u with gp 1 & 3 to assess for relapse.; Primary Outcome: HAM-D at 2 weeksnd and 2 weeks after treatment Interventions G1: 10 Hz rTMS to left DLPFC G2: 1 Hz rTMS to left DLPFC G3: 1 Hz toright DLPFC G4: Sham rTMS Medications allowed No psychotropic medications were allowed Parameters rTMS High Frequency:; - Frequency (Hz):10; - Motor threshold (%): 110; - Number of trains: 20; - Length of train (seconds): 8; - Inter-train interval: 52; - Pulses per session: 1600; - Total number of sessions: 10 days; Low Frequency LDLPFC:; - Frequency (Hz):1; - Motor threshold (%): 110; - Number of trains: 1; - Length of train (seconds): 1600; - Inter-train interval: 1; - Pulses per session: 1600; - Total number of sessions: 10 days; Low Frequency RDLPFC:; - Frequency (Hz): 1; - Motor threshold (%): 110; - Number of trains: 1; - Length of train (seconds): 1600; - Inter-train interval: 1; - Pulses per session: 1600; - Total number of sessions: 10 days; Sham rTMS:; - Orientation of coil perpendicular to scalp subdivided into 3 groups, replicating parameters for each group above; Strategy Switch | TRD definition; - All referred for ECT having failed an adequate course of antidepressant med; - Required to be in current episode; Tier 2 Inclusion criteria; - Patients w unipolar recurrent major depressive disorder (SCID & DSM-IV) HAM-D21 score ≥ 20; Exclusion criteria; - H/O any psychotic disorder (incl. schizophrenia or schizoaffective disorder); - Bipolar disorder; - Obsessive compulsive disorder; - Personality disorder; - SA(except nicotine) within past yr; - Current acute/chronic medical condition requiring txt with psychoactive medication; - H/O epilepsy or unprovoked seizures or other neurological disorder; - Abnormal neurological examination; - Family H/O medication-resistant epilepsy; - Prior brain surgery; - Metal in head; - Implanted medical device; - Pregnancy | Treatment Failure Mean failed trials NR Polarity, % Unipolar 100 % MDD Age, mean yrs G1: 53.2 G2: 52.3 G3: 52.8 G4: 53.3 Sex, % females G1: 60 G2: 60 G3: 70 G4: 60 Right handed, % 100 HAM-D 21 Baseline n G1: 10 G2: 10 G3: 10 G4: 15 Baseline score, mean (SD) G1: 27.8 (3.2) G2: 27.6 (3.9) G3: 27.9 (3.8) G4: 27.4 (2.9) | HAM-D 21 Endpoint score, mean (SD) At week 1 G1: 22.2 (5.6) G2: 27.6 (5.9) G3: 20.9 (4.1) G4: 25.6 (4.5) At week 2 G1: 15.1 (6) G2: 27.6 (5.9) G3: 15.8 (4.8) G4: 26.7 (3.6) Week 1 Follow-up G1: 12.8 (5.7) G2: 26.4 (2.3) G3: 15.3 (6.4) G4: 26.5 (2.3) Week 2 Follow-up G1: 13.4 (5.6) G2: 26.6 (3.0) G3: 14.9 (5.9) G4: 26.8 (2.3) Change, mean (SD) At week 2 G1: -12.7 G2: 0.0 G3: -12.1 G4: -0.7 % change, P = 0.001 2 week follow-up G1: 0 G2: 1.0 G3: 13.0 G4: 0.6 % change, P = 0.00001 Responders, n At week 1 G1: 0 G2: 0 G3: 0 G4: 0 At week 2 G1: 5 (50%) G2: 0 (0%) G3: 5 (50%) G4: 0 (0%) G1: > G2 + G4 and G3 > G2 + G4, (P < 0.0005) 1 week follow-up G1: 6 (60%) G2: 0 (0%) G3: 6 (60%) G4: 0 (0%) G1: > G2 + G4 and G3 > G2 + G4, (P < 0.0005) 2 week follow-up G1: 4 (40%) G2: 0 (0%) G3: 6 (6%) G4: 0 G1: > G2 + G4 and G3 > G2 + G4, (P < 0.0005) Remitters, n HAM-D ≤ 10 At week 1 G1: 0 (0%) G2: 0 (0%) G3: 0 (0%) G4: 0 (0%) At week 2 G1: 3 (30%) G2: 0 (0%) G3: 1 (10%) G4: 0 (0%) 1 week follow-up G1: 4 (40%) G2: 0 (0%) G3: 3 (30%) G4: 0 (0%) 2 week follow-up G1: 4 (40%) G2: 0 (0%) G3: 3 (30%) G4: 0 (0%) Responders followed for additional two weeks (endpoint 2wk follow-up) G1: vs. G3 P = NS (all times); G2 vs. G4 and G1: vs. G3 P = NS (all times) | Quality of Life NR Adverse Events 9/45 pts reported severe headaches (pts by group NR); no seizures Attrition Overall, %: 17.8 At end of treatment, % G1: 0 G2: 20 G3: 0 G4: 10 At end of follow-up, % G1: 0 G2: 50 G3: 0 G4: 20 Withdrawals due to efficacy: NR Withdrawals due to adverse events, % G1: 0 G2: 50 G3: 0 G4: 20 Though 8 pts withdrew due to AE, only 3 of those were listed as w/d during active period. Reported in text as dropped out following week 2. Adherence/ compliance NR
Author, Year Wiles et al., 2008^33^ Country, setting Bristol, UK, 3 general primary care practices, outpatient setting Funding NHS Research Objective In TRD, can you feasibly compare CBT + CM vs. CM in primary care (pilot study); primary outcome at 4 months Quality Rating Fair | Study design RCT Type of analysis ITT N 25 Duration 4 months Interventions G1: CBT + clinical management G2: Usual Care (clinical management) Medications allowed No restrictions Strategy Unlimited Parameters; - Type of therapy: CBT; - Method: NR; - Number of sessions/week: NR; - Total number of sessions: 12-20.; - Usual care (no restrictions) | TRD definition; - All patients had BDI 15 or more and had complied with an adequate medication; Tier 2 Inclusion criteria; - 18-65 years;; - BDI II score ≥ 15; - have complied with their antidepressant medication; - Met ICD-10 criteria for depression; Exclusion criteria; - Bipolar disorder, psychosis, personality disorder or major alcohol or substance abuse problems;; - Those who had been continually depressed for more than 5 years;; - Those unable to completestudy questionnaires;; - Previous CBT; - Those currently receiving other psychotherapy or secondary care for their depression | Subgroups None Treatment Failure Mean failed trials NR Polarity, % Unipolar Overall: 100 BDI Baseline n G1: 14 G2: 11 Baseline score, mean (SD) G1: 31.1 (8.5) G2: 26.8 (6.8) | BDI Endpoint score, mean (SD) NR Change, mean (SD) CBT+CM scores decreased by an average of 11.2 points more than CM alone (95%CI -19.3-3.1) Responders, n (%) G1: 8 (57.1) G2: 0 P = NR Remitters, n NR | Quality of Life Scale NR Baseline n NR Baseline score, mean (SD) NR Endpoint score, mean (SD) NR Change, mean (SD) NR There were no differences between groups in QOL at 4mos. (data NR) Adverse Events NR Neuropsychological or executive functioning No Measures, Results NR Predefined NA - No AE data reported MMSE NR Attrition Overall, % 8% At end of treatment, % G1: 0 G2: 18.2 At end of followup, % G1: 0 G2: 18.2 Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR Other NR Adherence/ compliance Compliance CBT patients could receive 12-20 sessions. AT 4 mos, median = 9.5 [IQR: 2, 12]. Patients attending <5 sessions (35.7%), patients attending 5-9 sessions (14.3%), patients attending >=10 sessions (50%).

Evidence Table 6 KQ1 active versus control: Tier 3

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Bortolomasi et al., 2006^34^ Country, setting Italy, single center, inpatient vs. outpatient NR Funding Not reported Research Objective To investigate outcome of depressed patients treated for 1 month with high frequency rTMS onleft frontal lobe at long time periods Quality Rating Fair | Study design RCT Type of analysis Cannot tell, all reported patients included in analysis N 19 Duration Active: 5* days Follow-up: 1, 4 and 12 weeks, co -primary endpoints HAM-D and BDI *duration of txt is unclear in article Interventions G1: rTMS G2: Sham Medications allowed Patients continued their (failed) ADs and no medications changes were allowed (5.3% were not taking medications at study entry) Strategy Augmentation Allowed to continue on failed SSRIs (63.2%) and TCAs (26.3%), No meds (5.3%) Parameters rTMS; - Frequency (Hz):20; - Motor threshold (%): 90; - Number of trains: 20; - Length of train (seconds): 2; - Inter-train interval: 60; - Pulses per session: 800; - Total number of sessions: 5/wk; - Circular coil; Sham; - Stimulation coil was placed perpendicular tothe scalp surface without direct contact. Coil position was fixed for all TMS sessions, and stimulation at this site evoked minimal motor activity | TRD definition; - Drug resistance (not defined); - Not required or not specified to be in current episode; Tier 3 Inclusion criteria; - DSM-IV clinical criteria for major depression, right-handed, normal neurological examinations; Exclusion criteria; - Hx of brain trauma or seizure disorder; - Pacemakers, mobile metal implants or implanted medication pumps | Treatment Failure Mean failed trials NR Polarity, % Unipolar G1: 83.3 G2: 85.7 Bipolar G1: 16.7 G2: 14.3 Age, mean yrs G1: range 45-56 G2: range 44-53 Overall: 55.6 Sex, % females G1: 58 G2: 57 Race, % white NR Right handed, % Overall: 100 Groups similar at baseline Yes Tier HAM-D 24 Baseline n G1: 12 G2: 7 Baseline score, mean (SD) G1: 25.17 G2: NR | HAM-D 24 Endpoint score, mean (SD) At week 1 G1: 11.33 G2: 18.29 At week 4 G1: 11.42 G2: 19.14 At week 12 NR Change, mean (SD) At week 1 G1: -13.84 G2: NR P = NR, significant Group × time at wk 2 and 4, P < 0.05 At week 4 G1: -13.75 G2: NR At week 12 NR IG1: rTMS G2: Sham Baseline n G1: 12 G2: 7 Baseline score, mean (SD) G1: 25.42 G2: NR Endpoint score, mean (SD) At week 1 G1: 12.25 G2: 22.43 At week 4 G1: 11.67 G2: 24.57 Change, mean (SD) At week 1 G1: 13.17G2: NR At week 4 G1: 13.75 G2: NR | Quality of Life NR Adverse Events No adverse effects were reported in either group, except for mild cephalgia by three patients treated with anti-inflammatory drugs Headache, % 3 patients reported mild headaches after treatment All rTMS patients referred to marked drowsiness for several hours immediately following. Six patients referred to subjective improvement of sleep after first stimulation session. Patients treated with sham condition did not report any symptoms related to drowsiness or sleep. 3 patients reported mild headaches after treatment Attrition Adherence/ compliance NR
Author, Year George et al., 1997^35^ Country, setting USA, outpatient setting Funding NARSAD, Ted and Vada Stlanley Foundation Research Objective To test hypothesis: daily left prefrontal rTMS has antidepressant effects Quality Rating Fair | Study design RCT, crossover Type of analysis ITT N 12 Duration 4 wk (2 wk intervention, 2 wk. follow-up) Primary outcome: Change in HAM-D after 2wks active txt Interventions G1: rTMS G2: sham stimulation Medications Allowed ADs tapered for 9, 3 partial responders continued their medication Strategy Mixed-within group differences Parameters rTMS; - Frequency (Hz):20; - Motor threshold (%): 80; - Number of trains: 20; - Length of train (seconds): 2; - Inter-train interval: NR; - Pulses per session:; - Total number of sessions: 5/wk for a total of 20 per patient; Sham:; - Same as above but angled at 45 degrees from skull | TRD definition; - Implied TRD, all patients had completed 1 or more medication trials but were depressed at study entry; - Not required or not specified to be in current episode; Tier 3 Inclusion criteria; - DSM-IV criteria for current MDD; - right-handed; Exclusion criteria; - Pts w abnormalities on general & neurological exam, urine drug screen, HIV test, MRI scan of head),; - Pacemakers; - H/O seizures; - H/O major head trauma | Treatment Failure Number of previous AD medications Overall: 13.4 Polarity, % Unipolar Overall: 91.7 Bipolar II Overall: 8.3 Age, mean yrs Overall: 41.8 (12.4) Sex, % females Overall: 91.7 Right handed, % Overall: 100 HAM-D 21 Baseline n G1: 12 G2: 12 Baseline score, mean (SD) Overall: 28.5 (4.2) | HAM-D 21 G1: rTMS G2: sham stimulation Change, mean (SD) At 2 weeks G1: -5.25 G2: +3.33 P < 0.03 | Quality of Life NR Adverse Events Headache, % G1: 4/12 G2: NR Suicidality, % G1: 0 G2: Sham: 1/12 Seizures: None Unexpected side effects: None Headaches NR by active v. sham Memory or Attention: None Attrition Overall: 0 Adherence/ compliance N
Author, Year Harley, 2008^36^ Country, setting United States, university clinics, outpatient psychiatric Funding Kaplan Fellowship Award Grant through Harvard Medical School Research Objective To assess feasibility and potential utility of a Dialectical Behavior Therapy(DBT)-based skills training group for TRD Quality Rating Fair | Study design RCT Type of analysis Completers N 24 Duration Primary outcome after 16 weeks of active txt Follow-up: 6 months Interventions G1: Dialectical Behavior Therapy(DBT)-based skills training G2: Wait-list Control Medications Allowed Patients continued antidepressant therapy Strategy Augmentation Parameters; - Type of therapy: Dialectical Behavior Therapy(DBT)-based skills training; - Method: Group; - Number of sessions/week:1; Total number of sessions:16 G2: Wait list | TRD definition; - 1+ failed medications (6+ weeks at “standard effective dose”); - Not required or not specified to be in current episode; Tier 2 Inclusion criteria; - 18-65 years with a principal diagnosis of MDD; - Established treatment relationship with a psychiatrist at MGH or in larger community.; - Stabalized on an adequate dose of antidepressant medication before entering study.; Exclusion criteria; - Borderline personaliy disorder, bipolar disorder, psychotic spectrum disorders, active substance abuse or dependence, mental retardation, or pervasive developmental disorder.; - Active suicidality requiring more intensive levels of care; - Severe or unstable medical conditions; - Previous or current CBT experience. | Baseline N G1: 13 G2: 11 Treatment Failure Mean failed trials NR Polarity, % MDD Overall: 100 Age, mean yrs Overall: 41.8 Sex, % females Overall: 75 Race, % white Overall: 83 HAM-D 17 Baseline score, mean (SD) G1: 16.15 (4.47) G2: 18.64 (4.72) P = NS BDI Baseline score, mean (SD) G1: 27.31 (8.83) G2: 27.44 (11.66) P = NS | HAM-D 17 Analyzed n G1: 10 G2: 9 Endpoint score, mean (SD) Completers analysis, 16 weeks G1: 11.30 (5.3) G2: 17.11 (6.23) Change, mean (SD) Completers, 16 weeks G1: -5.6 G2: -1.78 P < 0.05 Remitters, n Completers per protocol analysis, 16 weeks G1: 3 (23%*) G2: 0 (0%*) P = NR BDI Endpoint score, mean (SD) At Week 16, completers per protocol G1: 15.10 (12.13) G2: 25.89 (16.30) Change, mean (SD) G1: -12.80 G2: -1.55 P < 0.01 | Quality of Life Lifework-The Range of Impaired Functioning Tool (LIFE-RIFT) Baseline n G1: 10 G2: 9 Baseline score, mean (SD) G1: 4.00 (0.94) G2: 3.44 (1.24) Endpoint score, mean (SD) G1: 2.70 (1.34) G2: 3.11 (1.69) Change, mean (SD) G1: -1.3 G2: -0.33 P = NS Social Adjustment Scale-Self-Report (SAS-SR) work subscale Baseline n G1: 10 G2: 9 Baseline score, mean (SD) G1: 82.50 (21.21) G2: 69.22 (17.95) Endpoint score, mean (SD) G1: 65.70 (19.27) G2: 69.56 (17.66) Change, mean (SD) G1: -16.80 G2: 0.34 P < 0.05 Adverse Events NR MMSE NR Attrition Overall, %: 21 At end of treatment, % G123 G2:18 At end of follow-up, % G120 G2: NR Withdrawals due to efficacy, % G1: 8 G2: 0 Withdrawals due to adverse events, % 0 Other 5 participants (3 groups, 2 wait-lists) did not complete study. One group participant dropped out because of difficulty finding childcare another discontinued treatment due to a work schedule conflict, and third decided group was not a good fit. One wait-list participant moved and could not continue instudy and a medical problem prevented second from continuing. Adherence/ compliance Compliance Participants completed a weekly check-in form asking about medication compliance overpreceding month.19 participants who completed study reported that they had been largely medication compliant—11 reported that they had taken their medication as directed every day and 8 reported that they had forgotten a medication dose between 1 to 4 times in previous month.
Author, Year Moller, 2006^37^ Country, setting Iceland, hospital, inpatient and outpatient Funding Government or non-profit organization: Helga Jondottir and Sigurlioi Kristjansson Memorial Fund andLandspitali-University Hopsital of Iceland Research Fund Research Objective To evaluate antidepressant efficacy of 5 days of left prefrontal rTMS. Quality Rating Fair | Study design RCT, crossover Type of analysis Cannot tell if ITT, all reported patients included N 10 Duration Primary endpoint was within one week of completing txt Interventions G1: rTMS G2: Sham Medications allowed Pts continued (failed) AD medication and were allowed benzodiazepines Strategy Augmentation Parameters rTMS; - Frequency (Hz):10; - Motor threshold (%): 100; - Number of trains: 40; - Length of train (seconds): 5; - Inter-train interval: 25; - Pulses per session: 2000; - Total number of sessions: 5 in 5 days; Sham; - Stimulation was over the occipital cortex (stimulator angled 458 with both wings touching the scullStrategy; - Augment or add-on startegy | TRD definition; - TRD not defined; - Not required or not specified to be in current episode; Tier 3 Inclusion criteria; - Specific inclusion criteria are not reported.; - None ofpts received rTMS prior. All met safety criteria.; Exclusion criteria NR | Treatment Failure Mean failed trials NR Polarity, % Unipolar Overall: 80 Bipolar Overall: 20% Age, mean yrs Overall: 54 (14) Sex, % females Overall: 60% HAM-D 17 Baseline n G1: 7 G2: 3 Baseline score, median (range) G1: 20 (13 - 37) G2: 16 (7 - 31) | HAM-D 17 G1: rTMS G2: sham rTMS Endpoint score, median (range) G1: 13 (3 - 27) G2: 15 (4 - 25) Change, median-median G1: -7 G2: -1 P = 0.075 | Quality of Life NR Quality of Life NR Adverse Events Overall, % G1: 30% G2: 0 Amnesia, % NR Cardiovascular adverse events, % NR Cognitive impairment, % NR Dizziness, % NR Headache, % G1: 20%; 10% Migraine G2: Insomnia, % NR Post op complications, % NR Somnolence, % NR Suicidality, % NR Additional Comments Only reported on headaches and one migraine. authors do not elaborate on how A.E.s were elicited from pts. Simply, they state, “The magnetic stimulation was well tolerated.” Neuropsychological or executive functioning Yes; I don't know ifP300 fits in with neuropsychological testing but I've extracted all ofdata from it infollowing column Measures, Results P300 amplitude, n = 9; One pt could not relax and altered outcomes. The median entry P300 amplitude forpatients was 5.7 mV (range 1.0 - 9.5 mV) and latency was 335 ms (range 238 370).P300 amplitude changed from 5.7 mV (range 3.2 - 9.5) to 8.1 mV (range 3.3 - 11.6) after left prefrontal stimulation and after sham stimulation from 7.0 mV (range 1.0 - 13.4) to 8.0 (range 2.2 - 12.3). Comparison of changes inP300 amplitude (left prefrontal-group vs. sham-group) shows a significant difference (n = 9, Z = 2.0, P = 0.02). No significant changes were observed inP300 latency.counting performance did not show any difference before and after treatment. Predefined No MMSE NR Other Only reported on headaches and one migraine. authors do not elaborate on how A.E.s were elicited from pts. Simply, they state, “The magnetic stimulation was well tolerated.” Adequate information No Attrition Overall, % NR At end of treatment, % G1: NR G2: At end of follow-up, % G1: NR G2: Withdrawals due to efficacy, % G1: NR G2: Withdrawals due to adverse events, % G1: NR G2: Adherence/ compliance NR
Author, Year Paykel, 1999^38^ Scott, 2000^39^ Note: #2223 and #2219 are companion studies, data from #2223 were abstracted in to form for #2219. Country, setting UK, outpatient Funding Medical Research Council, London, England and a grant fromOxford and Anglia Region Research Objective To compare cognitive therapy combined with clinical management to clinical management alone for patients with residual depressive symptoms who continued to receive maintainance treatment with antidepressants. Quality Rating Good | Study design RCT Type of analysis ITT N 158 Duration Treatment period = 20 weeks; 48 wks - follow-up: Subjects were assessed every 4 to 20 wks and every 8 wks thereafter at baseline, 8 wks, 20 wks, and 68 wks. Interventions G1: Clinical management Only G2: CT plus Clinical Management Medications allowed Continued on current medications with dose adjustments allowed Strategy Augmention Parameters Psychotherapy:; - Type of therapy: Cognitive Therapy; - Method: Individual; - Number of sessions/week: 1.25/wk; - Total number of sessions: 16 | TRD definition; - residual symptoms reaching at least 8 on the 17-item Hamilton Depression Rating Scale (HDRS)18 and 9 on the Beck Depression Inventory (BDI) and taking a tricyclic antidepressant, serotonin reuptake inhibitor, atypical antidepressant, or monoamine oxidase inhibitor for at least the previous 8 weeks, with 4 or more weeks at a daily dose at least equivalent to 125 mg of amitriptyline,; - Residual symptoms had lasted 2 to 18 months.; - Failure required to be in the current episode; Tier 2 Inclusion criteria; - Unipolar depression,; - aged 21 to 65 years,; - satisfying DSM-III-R17 criteria for major depression withinlast 18 months but not inlast 2 months, and; - Had to be taking a tricyclic antidepressant, serotonin reuptake inhibitor, atypical antidepressant, or monoamine oxidase inhibitor for at leastprevious 8 weeks, with 4 or more weeks at a daily dose at least equivalent to 125 mg of amitriptyline, and higher levels unless there were definite current adverse effects or patient refusal to increase dose.; Exclusion criteria; - A history of bipolar disorder, cyclothymia, schizoaffective disorder, definite; - Intervention or alcohol dependence, persistent antisocial behavior or repeated self-harm,; - DSM-III-R dysthymia with onset before age 20 years,; - borderline personality, learning disability (estimated IQ,70),; - organic brain damage,; - any other primary Axis I disorder attime ofindex illness.; - Also excluded were patients currently receiving formal psychotherapy or those who had previously received CT for more than 5 sessions. | Treatment Failure Mean failed trials G1: NR G2: NR Polarity, % Unipolar 100% 100% Age, mean yrs G1: 43.2 (11.2) G2: 43.5 (9.8) Sex, % females G1: 53% G2: 46% HAM-D 17 Baseline n G1: 78 G2: 80 Baseline score, mean (SD) G1: 12.1(2.7) G2: 12.2 (2.9) P < 0.05 BDI Baseline score, mean (SD) G1: 22.3 (8.0) G2: 21.9 (7.7) | HAM-D 17 G1: Clinical Management only G2: CT plus Clinical Management Endpoint score, mean (SD) At week 20 G1: 9.40 (5.2) G2 (5.2) Follow-up at 44 weeks G1: 8.7 (5.3) G2: 7.6 (4.7) Follow-up at 68 weeks G1: 7.2 (4.7) G2: 7.2 (5.3) Change, mean (SD) At week 20 G1: -2.8 G2: -3.4 P = NS Follow-up at 44 weeks G1: - 3.0 G2: -4.5 Follow-up at 68 weeks G1: -5.0 G2: -4.9 Responders, n NR Remitters, n (%) HAM-D<8 At week 20 G1: 10 (13) G2: 19 (24) Hazard Ratio for remission from intention to treat analysis: 2.42 (95% CI, (1.08, 5.45)) BDI Endpoint score, mean (SD) At 20 weeks G1: 16.1 (10.0), G2: 13.8 (9.6), Follow-up at 44 weeks G1: 17.3 (11.6) G2: 12.3 (9.3) Follow-up at 68 weeks G1: 14.3 (10.9) G2: 13.5 (11.7) Change, mean (SD) At week 20 G1: -6.24 G2: -8.44 Responders, n NR Remitters, n BDI <9 At week 20 G1: 10 (13%) G2: 19 (24.4%) Relapse n(%): At week 20: G1: 18 (23) G2: 10 (13) At week 44 G1: 40 (51) G2: 24 (30) At week 68 G1: 47 (60) G2: 29 (36) Hazard ratio for relapse = 0.54 (0.32-0.93) in favor of CT Actuarial Cumulative relapse rates at all time points for group 1: Awk20 = 18%, FUwk44 = 40%, FUwk68 = 47%; Actuarial Cumulative relapse rates at all time points for group 2: Awk20 = 10%, FUwk44 = 24%, FUwk68 = 29%;adjusted hazard ratio for relapse = 0.51, 95% CI, (0.32, 0.93). Over 17 months,relapse rate was reduced from 47% among those who continued to be treated with antidepressants without CT to 29% among those who also received CT. #2219: Relapse was defined as: (1) meetingDSM-III criteria for major depressive disorder for a minimum of 1 month, and meeting severity criteria for major depression and score 17 or more onHAM-D 17 at 2 consecutive face-to-face assessments at least 1 week apart; (2) persistent residual symptoms duringfollow-up phase between 2 successive ratings 2 months apart, reaching a score onHAM-D 17 of at least 13 on both occassions and a level of distress or dysfunction for which the withholding of additional active treatment was no longer justified. | Quality of Life NR Adverse Events NR Attrition Overall, % 20% did not adhere to protocol through to study end or relapse point At end of treatment, % G1: 4 G2: 14 At end of follow-up, % G1: 12 G2: 10 Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR Adherence/ compliance Adherence, n(%) G1: 61 (76%) G2: 66 subjects (85) [Control]
Author, Year West, 1981^40^ Country, setting UK, Hospital, inpatient Funding NR Research Objective The therapeutic effect of simulated and real bilateral electric convulsion therapy Quality Rating KQ1 - Fair | Study design RCT Type of analysis Completers or per protocol (PP) N 25 (22 analysed) Duration 3 weeks Interventions G1: ECT G2: Simulated ECT Medications Allowed 50 mg amitryptyline Strategy Combination Parameters The anaesthetic agent was Althesin (alphadolone) and the muscle relaxant suxamethonium. Electric convulsion therapy was administered from a Transycon machine using 40 joules with double-sided unrectified waveform and bilateral anterior temporal placement of the electrodes. | TRD definition; - Referred for ECT; Tier 3 Inclusion criteria; - Primary depressive illness; Exclusion criteria; - NR | Subgroups NR Baseline n G1: 13 G2: 12 Treatment Failure NR Polarity, % NR Patient Characteristics Age, mean yrs G1: 52.0 G2: 53.3 Sex, % females G1: 45 G2: 36 Race, % white NR Not Specified, % NR Right handed, % NR Groups similar at baseline Yes HAM-D 17 Baseline score, mean (SD) BDI Baseline score, mean (SD) G1: 26.6 (SEM 2.8) G2: 24.1 (3.5) | N Analyzed G1: 11 G2: 11 BDI Yes G1: ECT G2: Simulated ECT Endpoint score, mean (SD) G1: 10.8 (SEM 2.6) G2: 22.2 (3.8) P < 0.002 Change, mean (SD) G1: -15.8 G2: -1.9 Responders, n NR Remitters, n NR Other | Quality of Life No Adverse Events NR Neuropsychological or executive functioning No Measures, Results None reported Predefined NA - No AE data reported Adequate information NA - No AE data reported Attrition Overall, % 12% At end of treatment, % G1: 15.4 G2: 8.3 At end of followup, % NR Withdrawals due to efficacy, % G1: 7.7 G2: 8.3 Withdrawals due to adverse events, % NR Other Adherence/ compliance None reported

Evidence Table 7 KQ1 Non-pharm versus pharm

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Bretlau, 2008^41^ Country, setting Denmark, setting NR, outpatients Funding Commercial source-please list name.supported by Medicon Valley Academy and an unrestricted research grant from H Lundbeck A/S Research Objective To do an interim analysis of a study on active rTMS combined with escitalopram versus sham TMS combined with escitalopram in the acute treatment phase. Quality Rating Fair | Study design RCT Type of analysis Modified ITT (m-itt) N 49 Duration; - 12 weeks, but primary outcome was at 3 weeks after 15 rTMS sessions completed over a three week period.; - Escitalopram was administered during entire trial at 20mg daily (10 mg daily for first wk of trial).; - Primary outcome (HAM-D6) was recorded at baseline, wk 2, 2k 3, 2k 5, 2k 8, and wk 12. Secondary outcome measures (HAM-D17 and MES) were recorded at the same intervals.; Interventions B - Repetetive Transcranial Magnetic Stimulation (rTMS)E - Placebo G1: rTMS + escitalopram (n = 25) G2: sham TMS + escitalopram (n= 24) G1: rTMS + escitalopram G2: sham TMS + escitalopram G1: rTMS + escitalopram** G2: sham TMS + escitalopram** Parameters Location = Left Dorslateral prefrontal cortex Frequency = 8 Hz Intensity = 90% motor threshold Per session = 20 trains of 8 seconds at 52-second intervals. Each txt session lasted 20 minutes. Number of sessions = 15 Strategy Augment or add-on strategy, for example the patients current treatment of an SSRI was added to or augmented with another treatment | TRD definition required to be in current episode Yes Tier 2 Setting(s) Not clearly reported Inclusion criteria; - Aged 18 - 75 years;; - meet DSM-IV criteria for current major depressive disorder but not chronic subtype (i.e. current episode not > 24 months);; - failed to respond to at least one previous adequate (at least 6 weeks) antidepressant treatment during the current episode;; - subjects with heart disorders or diabetes were included if they were in a somatically stable phase; Exclusion criteria; - Concurrent diagnosis of an organic brain disorder such as mental retardation, schizophrenia, or other psychotic disorders or personality disorders;; - potential risk factors for escitalopram such as hypersensitivity to the Intervention,; - intake of monoamine-oxidase inhibitors of the irreversible type with the past 14 days,; - pregnancy or insufficient contraception in females of reproductive age;; - risk factors for TMS such as history of epilepsy,; - metal implants in the head or neck regions,; - pacemaker or other electronic implants,; - receiving antipsychotics;; - having major suicide ideation. | Subgroups No sub-group analysis Treatment Failure Failed 1 or more, % G1: 100 G2: 100 Failed 2 or more, % NR Current episode failures, mean G1: 2.8 (0.9) G2: 2.5 (0.9) Mean failed trials NR Polarity, % Unipolar NR Patient Characteristics Age, mean yrs G1: 53.1 G2: 57.8 Sex, % females G1: 68% G2: 57% Race, % white NR Not Specified, % NR Right handed, % NR Baseline n G125 G2:24 Groups similar at baseline Yes HAM-D17 Baseline score, mean* (SD) G1: HAM-D 17 = 25.3 (3.0); HAM D 6 = 14.0 (1.0) G2: HAM-D 17 = 24.7 (3.2); HAM D 6 = 13.3 (1.5) *based on rTMS: n = 22 sham: n = 23 | HAM-D17 G1 G2:Endpoint score, mean (SD) G1: HAM-D 17: Awk2 = 19.8 (5.1),G1: = 16.4 (4.5), FU wk 5 = 14.5 (5.2), FU wk8 = 12.4 (5.8), FU wk12 = 11.1 (6.7); HAM D 6 = Awk2 = 11.5 (2.6), Awk 3 = 10.0 (2.5), FU wk 5 = 8.9 (2.6), FU wk 8 = 7.9(3.1), FU wk 12 6.7 (4.1) G2: HAM-D 17: = A wk 2 = 22.3(4.5), A wk 3 = 19.1 (4.8), FU wk 5 = 16.3 (5.1), FU wk 8 = 15.3 (6.4), FU wk 12 = 13.5 (7.2); HAM D 6: Awk 2 = 12.5(2.3), A wk 3 = 11.4 (2.7), FU wk 5 = 10.0 (2.9), FU wk 8 = 8.9 (3.6) FU wk 12 = 8.1 (4.2) Change, mean (SD) G1: HAM-D 17 = 14.2 ; HAM D 6 = 7.3 G2: HAM-D 17 = 11.2; HAM D 6 = 5.2 Responders, n G1: NR G2: NR Remitters, n G1: NR G2: NR Other; - The effect size on the primary outcome measure (HAM-D 6) was greatest after two weeks of therapy (0.80 in favor of rTMS), but after 3 weeks of therapy, the effect size was 0.65 (still > 0.40). It remained above 0.40 at the 12 week endpoint (0.47).; - HAM-D17 Awk 2 Effect size (95% CI) and Mann-Whitney P = 0.83 (0.22-1.44), P = 0.02; HAM-D17 Awk 3 Effect size (95% CI) and Mann-Whitney P: 0.78 (0.18 - 1.39), P = 0.01; HAM-D17 FU wk 5 Effect size (95% CI) and Mann-Whitney P: 0.48(-0.12 - 1.07), P = 0.09; HAM-D17 FU wk 8 Effect size (95% CI) and Mann-Whitney P: 0.64 (0.04 - 1.24), P = 0.05; HAM-D17 FU wk 12 Effect size (95% CI) and Mann-Whitney P: 0.47 (-0.11 - 1.07), P = 0.22;; - HAM-D6 Awk 2 Effect size (95% CI) and Mann-Whitney P: 0.73 (.018 -1.39), P = 0.05; HAM-D6 Awk 3 Effect size (95% CI) and Mann-Whitney P: 0.80 (0.20 - 1.42), P = 0.01; HAM-D6 FU wk 5 Effect size (95% CI) and Mann-Whitney P: 0.65 (0.09 -1.29), P = 0.02; HAM-D6 FU wk 8 Effect size (95% CI) and Mann-Whitney P:0.50 (-0.10 -1.09), P = 0.10; HAM-D6 FU wk 12 Effect size (95% CI) and Mann-Whitney P: 0.0.50 (-0.10 - 1.09), P = 0.09;; BDI G1: rTMS + escitalopram* (See comments) G2: sham TMS + escitalopram Baseline n G1: n @ baseline = 25; M-ITT = 23 G2: n@ baseline = 24; M-ITT = 22 Baseline score, mean (SD) G1: 23.9 (2.4) G2: 23.0 (3.0) Endpoint score, mean (SD) G1: A wk 2 = 19.5 (4.4), A wk 3 = 16.5 (4.7), FU wk 5 = 14.2 (4.7), FU wk 8 = 12.8, FU wk 12 = 11.5 (6.8) G2: A wk 2 = 21.3 (4.1), A wk 3 = 19.2 (4.4), FU wk 5 = 16.4 (5.2), FU wk 8 = 15.4 (6.2), FU wk 12 = 13.6 (6.9) Change, mean (SD) G1: 12.4 G2: 9.4 Responders, n NR Remitters, n NR Other *Bech-Rafaelsen Melancholia scales (MES) reported NOT BDI MES Awk 2 Effect size (95% CI) and Mann-Whitney P = 0.73 (0.12 - 1.33), P = 0.03; Awk 3 Effect size (95% CI) and Mann-Whitney P: 0.84 (0.24 -1.46), P = 0.00; FU wk 5 Effect size (95% CI) and Mann-Whitney P: 0.64(0.02 - 1.22), P = 0.03; FU wk 8 Effect size (95% CI) and Mann-Whitney P: 0.65 (0.04 - 1.24), P = 0.03; FU wk 12 Effect size (95% CI) and Mann-Whitney P: 0.46 (-0.12 - 1.06), P = 0.12; MADRS NR IDS NR CGI-S NR CGI-I NR Instrument Major Depression Inventory (MDI) Baseline n G1: n @ baseline = 25; M-ITT = 23 G2: n@ baseline = 24; M-ITT = 22 Baseline score, mean (SD) G1: 33.5 (5.1) G2: 34.0 (5.6) Endpoint score, mean (SD) G1: A wk 2 = 23.8 (9.0), A wk 3 = 21.5 (9.8), FU wk 5 = 20.1 (9.0), FU wk 8 = 18.4 (10.0), FU wk 12 = 16.1 (10.7) G2: A wk 2 = 27.9 (10.6), A wk 3 = 26.6 (9.9), FU wk 5 = 23.7 (9.5), FU wk 8 = 21.5 (11.0), FU wk 12 = 19.6 (12.8) Change, mean (SD) G1: 17.4 G2: 14.4 MDI Awk 2 Effect size (95% CI) and Mann-Whitney P = 0.36 (-0.23 - 0.94), P = 0.18; Awk 3 Effect size (95% CI) and Mann-Whitney P:0.43 (-0.16 - 1.03), P = 0.29; FU wk 5 Effect size (95% CI) and Mann-Whitney P: 0.29 (-0.29 -0.88), P =0.20; FU wk 8 Effect size (95% CI) and Mann-Whitney P: 0.22 (-0.36 - 0.81), P = 0.72; FU wk 12 Effect size (95% CI) and Mann-Whitney P: 0.23 (-0.36 -0.81), P = 0.43; | Quality of Life NR Adverse Events Overall NR Amnesia, % G1: memory impairment: 3wk/ 12 wk mean: 0.00/0.00 G2: 0.13/0.00 Cardiovascular adverse events, % G1: palpatations: 3wk/ 12 wk mean: 0.23/0.14 G2: 0.30/0.12 Cognitive impairment, % G1: concentration difficulties 3wk/ 12 wk mean: 1.43/0.71 G2: 1.52/1.22 Headache, % G1: 3wk/ 12 wk mean: 0.18/0.10 G2: 0.43/0.06 Insomnia, % G1: reduced duration of sleep 3wk/ 12 wk mean: 0.45/0.24 G2: 0.91/0.39 Additional Comments **Adverse events are reported by the UKU side-effect scale and reported as mean and standard deviation** Sig differences (P <= 0.05) compared to active: at 3wks, with sham pts have higher reduction in sleep; at 12 wks, more sham pts have concentration difficulties Study utilized the UKU scale as listed before - Other adverse events inlcude: tension/inner unrest: Sham AK wk 3 = 1.48 (0.67)/ FU wk 12 = 0.89 (0.32); rTMS A wk 3 = 1.36 (0.49), FU wk 12 1.00 (0.63); Tremor: Sham AK wk 3 = 0.17 (0.39)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.14 (0.35), FU wk 12 0.05 (0.12); Akathisia: Sham AK wk 3 = 0.04 (0.21)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.05 (0.21), FU wk 12 0.00 (0.00); Nausea: Sham AK wk 3 = 0.35 (0.49)/ FU wk 12 =0.17 (0.51); rTMS A wk 3 = 0.14 (0.35), FU wk 12 0.05 (0.22); Diarrhea: Sham AK wk 3 = 0.09 (0.29)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.14 (0.35), FU wk 12 0.10 (0.30); Diminished Sexual Desire: Sham AK wk 3 = 1.45 (0.74)/ FU wk 12 =0.94 (0.73); rTMS A wk 3 = 1.27 (0.94), FU wk 12 0.71(0.56); Dry Mouth: Sham AK wk 3 = 0.43 (0.56)/ FU wk 12 = 0.11 (0.32); rTMS A wk 3 = 0.27 (0.46), FU wk 12 0.14(0.36); Micturia: Sham AK wk 3 = 0.09 (0.29)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.05 (0.22), FU wk 12 0.00 (0.00); Neuropsychological or executive functioning No Measures, Results NR Predefined Yes MMSE No NR Baseline n NR Baseline score, mean (SD) NR Endpoint score, mean (SD) NR Change, mean (SD) NR Other Other Yes Study utilized the UKU scale as listed before - Other adverse events inlcude: tension/inner unrest: Sham AK wk 3 = 1.48 (0.67)/ FU wk 12 = 0.89 (0.32); rTMS A wk 3 = 1.36 (0.49), FU wk 12 1.00 (0.63); Tremor: Sham AK wk 3 = 0.17 (0.39)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.14 (0.35), FU wk 12 0.05 (0.12); Akathisia: Sham AK wk 3 = 0.04 (0.21)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.05 (0.21), FU wk 12 0.00 (0.00); Nausea: Sham AK wk 3 = 0.35 (0.49)/ FU wk 12 =0.17 (0.51); rTMS A wk 3 = 0.14 (0.35), FU wk 12 0.05 (0.22); Diarrhea: Sham AK wk 3 = 0.09 (0.29)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.14 (0.35), FU wk 12 0.10 (0.30); Diminished Sexual Desire: Sham AK wk 3 = 1.45 (0.74)/ FU wk 12 =0.94 (0.73); rTMS A wk 3 = 1.27 (0.94), FU wk 12 0.71(0.56); Dry Mouth: Sham AK wk 3 = 0.43 (0.56)/ FU wk 12 = 0.11 (0.32); rTMS A wk 3 = 0.27 (0.46), FU wk 12 0.14(0.36); Micturia: Sham AK wk 3 = 0.09 (0.29)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.05 (0.22), FU wk 12 0.00 (0.00); Adequate information Yes Attrition Overall, % 3 RTMS patients did not complete protocol, and 1 sham patient did not complete (analysis used last observation carried forward). At 3 week outcome, all 45 patients in m-ITT were present. By end of study at 12 weeks, 6/49 (12%) had dropped out. At end of treatment, % G1: At end of rTMS (3 wks) = 0 G2: At end of Sham (3 wks) = 0 At end of follow-up, % G1: 21% G2: 4% Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR Adherence/ compliance NR
Author, Year Folkerts et al., 1997^42^ Country, setting Germany, single center, inpatients Funding Not reported Research Objective To compare ECT in a controlled, randomized study withserotonin reuptake inhibitor paroxetine in treatment-resistant depression. Quality Rating Fair | Study design RCT Type of analysis per protocol N 39 Duration Total 6 weeks; Washout >= 3days; Phase I ECT - 2wks, Paroxetine - 4 wks; Phase II Paroxetine group - if clinical improvement reduction < 50% treatment switched to ECT, ECT group crossed over to Paroxetine or other antidepressants. Interventions G1: ECT G2: Paroxetine Medications Allowed After med wash -out patients were allowed a tranquillizer (diazepam up to 5 mg daily), a sedative (lormetazepam 0.5- 1.0 mg or triazolam 0.25 mg) or a sedative neuroleptic (pipamperon, up to 40 mg daily). Parameters ECT:; - % receiving bilateral: 0; - Intensity: 2.5-fold seizure threshold; - Number of sessions (range, mean, SD): 3/wk, range 6 to 9, mean 7.2 session; Paroxetine; - Started at 20 mg/day, within 7 days increased to 40 mg, allowed up to 50 mg, mean dose 44 mg/day for at least 4 weeks; Strategy Switch | TRD definition; - 2+ failed treatmentd (8+ weeks) including at least 1 tricyclic, at a dosage of at least 100 imiprimine equivalents; - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - Major depressive episode single and recurrent; - Bipolar disorders; - HAM-D21 >=22; Exclusion criteria; - Psychosis; - Pronounced suicidal tendency; - Severe physical illness; - History of substance abuse; - previous paroxetine or ECT treatment | Treatment Failure Level of tx resistance (Kuhs, 1995) G1: 1.9 (0.7 SD) G2: 2.0 (0.8 SD) Mean failed trials G1: 4.9 G2: 4.3 Polarity, % Unipolar G1: 90.5 G2: 83.3 Bipolar G1: 9.5 G2: 16.7 Age, mean yrs G1: 47.6 G2: 52.3 Sex, % females G1: 62 G2: 44 HAM-D 21 Baseline n G1: 21 G2: 18 Baseline score, mean (SD) G1: 31.1 (4.9) G2: 32.6 (5.4) | HAM-D 21 Endpoint score, mean (SD) Endof Phase I (ECT: 2-3 wks, Paroxetine: 4 wks) G1: 12.5 (3.9) G2: 23.0 (10.4) Endof Phase II (open trial, 6 weeks) G1: 12.8 (5.1) G2: 15.2 (7.9) Change, mean (SD) End of Phase I G1: -18.6 G2: -9.6 % Reduction in HAM-D, P = 0.001 End of Phase II G1: 18.3 G2: 17.4 Responders, n End of Phase I G1: 15 (71.4%) G2: 5 (27.8%) P= 0.006 | Quality of Life NR Adverse Events NR Attrition Overall, % 0 - all patients continued toscheduled end of treatment At end of treatment, % 0 At end of follow-up, % 0 Withdrawals due to efficacy, % 0 Withdrawals due to adverse events, % 0 Adherence/ compliance; - All pts continued their respective therapsies through scheduled end of treatment Phase I; - 11 of 21 ECT were able to discontinue after 6th ECT session and 10 pts. had 3 additional ECT treatments.; - Phase II - of ECT group, 9 received paroxetine and 12 received other antidepressants; - Of paroxetine groups, 7 crossed over to ECT; - 11 received antidepressants - 7 paroxetine and 4 received other antidepressants; - 1 person was excluded from analysis due to failure to increase treatment dosage
Author, Year Moore et al., 1997^43^ Country, setting Scotland, University clinic, outpatients Funding Scottish Office, Home and Health Department Research Objective To compare CBT to additional meds in treatment of depression non-responsive to medication duringacute phase of study (results of Phase 1 reported elsewhere). Quality Rating Fair | Study design RCT Type of analysis Completers confirmed with ITT N 13 Duration 12 months Interventions G1: Medication G2: Cognitive Therapy Medication Allowed G1: Continued AD assigned in acute phase OR initiated another AD txt G2: Discontinued AD Strategy Mixed-between group differences Parameters; - Medication dose within recognized therapeutic threshold; - Psychotherapy; - Type of therapy: Cognitive Therapy; - Method: NR; - Number of sessions/week: min. 3/wk for 4wks and then 2/wk for 4wks and 1/wk for 4wks; - Total number of sessions: NR | TRD definition; - Failure to respond to AD medication during 16 wk acute txt phase; - Failure required to be in current episode; Tier 2 Inclusion criteria; - HAM-D > 14; Exclusion criteria NA | Baseline N G1: 6 G2: 7 Treatment Failure Current episode failures, mean G1: NR G2: NR Mean failed trials G1: NR G2: NR Polarity, % Unipolar Overall: 100 Age, mean yrs Overall: 38 Sex, % females Overall: 62 HAM-D 17 Baseline score, mean (SD) G1: 18.6 (3.3) G2: 18.3 (3.9) BDI Baseline score, mean (SD) G1: 30.6 (5.1) G2: 37.8 (5.1) | Analyzed, n G1: 4 G2: 5 HAM-D 17 Endpoint score, mean (SD) 4 mos G1: 11.0 (2.3) G2: 19.8 (5.6) 8 mos G1: 6.6 (7.3) G2: 17.5 (1.9) 12 mos G1: 5.0 (5.7) G2: 14.3 (4.0) Completers, group by time, P < 0.01 ITT (LOCF), group by time, P < 0.01 Change, mean (SD) 4 month G1: -7.6 G2: +1.5 Partial responders, n Defined as HAM-D ≤ 14 G1: 5 G2: 2 P = 0.17 Full responders, n Defined as HAM-D ≤ 6 G1: 3 G2: 0 P = NR BDI Endpoint score, mean (SD) 4 mos. G1: 22.2 (5.9) G2: 41.5 (5.8) 8 mos. G1: 9.2 (8.3) G2: 34.3 (12.0) 12 mos. G1: 10.8 (12.2) G2: 35.8 (12.6) Group by time, P = 0.05 ITT (LOCF), group by time, P < 0.05 Change, mean (SD) At 4 months G1: -8.4 G2: +3.7 Partial responders, n Defined as BDI ≤ 16 G1: 4 G2: 0 P < 0.05 Full responders, n Defined as BDI ≤ 9 G1: 3 G2: 0 P = NR | Quality of Life NR Adverse Events NR Attrition Overall, % 31% At end of treatment, % G1: 43 G2: 17 At end of follow-up, % G1: 43 G2: 17 Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR Adherence/ compliance NR
Author, Year Thase et al, 2007^44^ Country, setting United States, 18 primary care and 23 psychiatric care practice settings, outpatients Funding National Institutes of Mental Health Research Objective To compare the effectiveness of cognitive therapy and pharmacotherapy as second-step strategies for outpatients with major depressive disorder who had received inadequate benefit from an initial trial of citalopram. Quality Rating Fair | Study design Equipoise-stratified randomization Type of analysis ITT N 304 Duration up to 14 weeks; Interventions G1: Augmentation Cognitive Therapy G2: Augmentation Medication G3: Switch Cognitive Therapy G4: Switch Medication Medications allowed See parameters Strategy Mixed- between group differences Parameters G1: Augmentation to citalopram with Cognitive Therapy: 16 sessions in 12 weeks G2: Augmentation to citalopram with sustained-release bupropion, buspirone G3: Switch from citalopram to cognitive therapy: 16 session in 12 weeks G4: Switch from citalopram to sertraline, sustained-release bupropion, or extended-release venlafaxine | TRD definition; - Failed at least one adequate (8 wks or more) treatment in the current episode; Tier 2 Inclusion criteria 18 to 75 years; non-psychotic major depressive disorder. HAM-D 17 > 14 Exclusion criteria; - Remission in initial phase; - Bipolar disorder; - Schizophrenia, schizo affective disorder, or psychosis not otherwise specified; - Anorexia or bulimia; - Obsessive compulsive disorder; - Clear-cut intolerability to, or lack of effect with, an adequate trial of at least 1 protocol medication or other SSRI in current episode of MDD; - Non response to 16 or more sessions of CT or > 7 ECT; - General medical condition or medication that contraindicates any level 1 or 2 treatment option; - Immediate hospitalization for substance/alcohol detoxification or treatment or psychiatric disorder(s).; - Antipsychotic medication or mood stabilizers; - Pregnant | Treatment Failure Mean failed trials NR Polarity, % 100% MDD Age, mean yrs G1: 40.6 G2: 39.7 G3: 43.4 G4: 41.5 Sex, % females G1: 63.1 G2: 66.7 G3: 61.1 G4: 61.6 Race, % white G1: 80.0 G2: 84.6 G3: 77.8 G4: 73.3 HAM-D 21 Baseline n G1: 65 G2: 117 G3: 36 G4: 86 Baseline score, mean (SD) G1: 17.8 (5.7) G2: 16.0 (6.7) P = 0.0962 G3: 16.4 (6.2) G4: 17.7 (6.6) P = 0.3492 QIDS-SR Mean Score at Baseline G1: 11.9 (4.3) G2: 12.0 (4.6) P = 0.9495 G3: 11.2 (4.3) G4: 12.1 (4.6) P = 0.3282 | HAM-D 21 Change, mean (SD) NR Remitters, n (%) HAM-D < 8 G1: 15 (23.1%) G2: 39 (33.3%) P = 0.1967 G3: 9 (25.0%) G4: 24 (27.9%) P = 0.6881 QIDS-SR Mean Score at Endpoint G1: 8.2 (5.1) G2: 8.2 (4.8) P = 0.9490 G3: 9.1 (5.4) G4: 9.1 (5.0) P = 0.9734 Mean Score Change G1-29.8 (40.5%) G2: -28.3 (39.6%) P = 0.8302 G3: -15.6 (40.7%) G4: -17.2 (46.2%) P = 0.9040 Responders, n (%) G1: 23 (35.4%) G2: 33 (28.2%) P = 0.2493 G3: 8 (22.2%) G4: 23 (26.7%) P = 0.8390 Remitters, n (%) QIDS-SR <6 G1: 20 (30.8%) G2: 39 (33.3%) P = 0.7803 G3: 11 (30.6%) G4: 23 (26.7%) P = 0.9032 | Quality of Life Baseline n G1: 65 G2: 117 G3: 36 G4: 86 Baseline score, mean (SD) G1: 41.8 (13.5) G2: 47.7 (14.9), P = 0.0202 G3: 43.3 (14.7) G4: 45.5 (13.4), P = 0.4634 Endpoint score, mean (SD) NR Change, mean (SD) NR Adverse Events Maximum side effect frequency P = 0.1059 No side effects, n (%) G1: 20 (33.3) G2: 19 (17.3) G3: 2 (100) G4: 14 (18.4) 10–25% of the time, n (%) G1: 16 (26.7) G2: 38 (34.5) G3: 0 (0.0) G4: 25 (32.9) 50–75% of the time, n (%) G1: 13 (21.7) G2: 33 (30.0) G3: 0 (0.0) G4: 18 (23.7) 90–100% of the time, n (%) G1: 11 (18.3) G2: 20 (18.2) G3: 0 (0.0) G4: 19 (25.0) Maximum side effect intensity, P = 0.1164 No side effects, n (%) G1: 19 (31.7) G2: 19 (17.3) G3: 2 (100) G4: 13 (17.1) Minimal to mild, n (%) G1: 16 (26.7) G2: 33 (30.0) G3: 0 (0.0) G4: 26 (34.2) Moderate to marked, n (%) G1: 21 (35.0) G2: 42 (38.2) G3: 0 (0.0) G4: 27 (35.5) Severe to intolerable, n (%) G1: 4 (6.7) G2: 16 (14.5) G3: 0 (0.0) G4: 10 (13.2) Maximum side effect burden, P = 0.1314 No side effects, n (%) G1: 22 (36.7) G2: 24 (21.8) G3: 2 (100) G4: 18 (23.7) Minimal to mild, n (%) G1: 25 (41.7) G2: 47 (42.7) G3: 0 (0.0) G4: 32 (42.1) Moderate to marked, n (%) G1: 11 (18.3) G2: 32 (29.1) G3: 0 (0.0) G4: 22 (28.9) Severe to intolerable, n (%) G1: 2 (3.3) G2: 7 (6.4) G3: 0 (0.0) G4: 4 (5.3) Exited because of intolerance, n (%) G1: 6 (9.2) G2: 22 (18.8), P = 0.0863 G3: 6 (16.7), G4: 23 (26.7), P = 0.2330 At least 1 serious adverse event, n (%) G1: 4 (6.2) G2: 4 (3.4), P = 0.4588 G3: 0 (0.0) G4: 2 (2.3), P = 1.0000 At least 1 psychiatric serious adverse event, n (%) G1: 4 (6.2) G2: 1 (0.9), P = 0.0556 G3: 0 (0.0) G4: 0 (0.0) Attrition Overall % NR Adherence/ compliance Completed ≥ CBT session G1: 17 (27.4%) G2: NR G3: 10 (34.5%) G4: NR
Author, Year Dannon, 2002^45^ Country, setting Israel; medical center outpatient program Funding National Association for Research in Schizophrenia and Affective Disorders NARSAD) and Stanley Research Foundation Research Objective To compare longitudinal outcomes of patients who responded to either rTMS or ECT Quality Rating Fair | Study design Observational Type of analysis Study references Grunhaus 2000 (Refid #368) which is open study of 40 patients - suspect this is continuation of this with additional patients. Of 43 responders initially identified, 2 are excluded N 43 Duration 3 month and 6 month follow-up; Primary outcome was presence or absence of relapse at 3 or 6 months. Relapse defined as return of depressive symptomatology meeting DSM-IV criteria for MDD with a HAM-D17 score of >= 16 points Interventions A - Electroconvulsive Therapy (ECT)B - Repetetive Transcranial Magnetic Stimulation (rTMS) G1: ECT G2: rTMS Antidepressants prescried at end of ECT and rTMS for all patients Parameters rTMS: Location = Left Dorsolateral Prefrontal Cortex Frequency = 10Hz Intensity = 90% MT Per Session = 6 sec trains with 30 sec interval in between at 20 times. Number of sessions = daily for 20 days ECT Methods: Location: Initially unilateral; switched to bilateral txt after 6th txt if HRSD had not decreased by >= 30% Threshold = 2.5 times threshold energy to maintain a seizure length of >= 25 sec. Number of sessions = NR Strategy There is no description of whether participats were taking medications prior to treatment with ECT or rTMS. Co-medications were not allowed during period when ECT or rTMS was given with exception of lorazepam. Antidepressants | TRD definition; - Not required or not specified to be in current episode; Setting(s) Outpatient Inclusion criteria; - Responded to treatment with either ECT or rTMS; - over age 18 years; - DSM-IV diagnosis of MDD with or without psychotic features; - no personal or first-degree family history of seizure; - no major medical, neurologic, or neurosugical disorder.; - Response for inclusion defined as HAM-D17 <= 10 or demonstrating 60% drop in HAM-D and final global assessment scale (GAS) >=60; Exclusion criteria NR in this article - but Grunhaus 2000 (Refid #368) reports that patients with additional axis-I diagnoses were excluded from the study | Subgroups No sub-group analysis of psychosis although permitted in study Treatment Failure Patients referred for ECT because of nonresponse or psychotic MDD Failed 1 or more, % G1: NR G2: NR Failed 2 or more, % G1: NR G2: NR Current episode failures, mean G1: NR G2: NR Mean failed trials G1: NR G2: NR Previous treatment, not specified, % G1: NR G2: NR Polarity, % Unipolar G1: NR G2: NR Bipolar I G1: NR G2: NR Bipolar II G1: NR G2: NR Age, mean yrs G1: 57.43 G2: 56.85 Sex, % females G1: 70% Note: there might be a typo in table in reporting gender ratio, percentage reported here is based on numbers in “rTMS” column in paper because they add up to correct n for “ECT column.” G2: 66.7% Race, % white G1: NR G2: NR Right handed, % G1: NR G2: NR Groups similar at baseline No- what are differences All P values were reported as non-significant for baseline characteristics, however following characteristics showed some variation between groups: Duration of episode (months) (mean +/- SD), ECT grouP = 6.71 +/-7.56, rTMS gr Tier Tier 3 only mention of whetherparticipants failed any previous treatments is in Grunhaus (#368). | HAM-D 17 Baseline n G1: 20 G2: 21 Baseline score, mean (SD) G1: 7.90 (4.54) G2: 7.75 (3.74) Endpoint score, mean (SD) At 3 months G1: 7.71 (5.03) G2: 6.40 (4.91) At 6 months G1: 8.40 (5.60) G2: 7.90 (7.14) Change, mean (SD) At 3 months G1: -0.01 G2: 1.35 At 6 months G1: -0.5 G2: -0.15 Responders, n NR Remitters, n NR Relapse (HAM-D ≥ 16) At 3 months G1: 2 G2: 1 At 6 months G1: 2 G2: 3 Combined G1: 4 G2: 4 Other HAM-D17 3 mos = P = NS, CI -1.83, 4.46; 6 mos = P = NS, CI -3.61, 4.61 ECT vs. rTMS BDI NR MADRS NR IDS NR CGI-S NR CGI-I No NR Baseline n NR Endpoint score, mean (SD) NR Achieving 1 or 2 score, %(SD) NR Other NR Other | Quality of Life Global Assessment of Functioning (GAF), or GAS Baseline n G1: 20 G2: 21 Baseline score, mean (SD) G1: 71.81 (10.39) G2: 72.50 (9.39) Endpoint score, mean (SD) At 3 months G1: 75.52 (13.81) G2: 79.75 (12.92) At 6 months G1: 72.8 (11.94) G2: 77.75 (17.13) Change, mean (SD) At 3 months G1: -3.71 G2: -7.25 At 6 months G1: -0.99 G2: -5.25 Other 3 mos P = NS, CI -12.69, 4.23; 6 mos P = NS, CI -14.40, 4.50 Adverse Events NR Neuropsychological or executive functioning No Measures, Results NR Predefined NA - No AE data reported MMSE NR Attrition Overall, % 4.6% At end of treatment, % NR At end of follow-up, % G1: 0 G2: 9 Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % G1: NR G2: NR Other 43 people agreed to be part of study, two were dropped before final analysis, no explanation is given, and they are not included in final analysis. The Michigan Adequacy of Treatments (MATS) was also included in this study. MATS for ECT was 3 mos FU 1.92 (1.04 SD), 6 mos FU 1.82 (0.98 SD); rTMS 3 mos FU 2.28 (1.07 SD), 6mos 2.44 (1.03 SD). CI for 3 mos FU ECT vs. rTMS is -1.14 - 0.43, P = N Adherence/ compliance NR

Evidence Table 8 KQ1 pharm versus pharm: Tier 1

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Berman, 2007^46^ Berman Country, setting United States Multicenter, outpatient setting Funding Bristol-Myers Squibb Co Otsuka Pharmaceutical Co Research Objective To compare the efficacy, safety, and tolerability of aripiprazole vs. placebo as adjunctive treatment to standard antidepressant therapy in the treatment of an MDE in pts who have shown an incomplete response to ADT Quality Rating Fair | Study design RCT Type of analysis Modified ITT (m-ITT) N Prospective tx phase: 781 Double-blind tx phase: 366 (4 did not receive medication and were not included) Duration Prospective tx phase: 8 wks Double-blind tx phase: 6 wks Primary outcome MADRS total score at endpoint 8 wks. Additional efficacy measures collected weekly. Interventions Antidepressant + (Augmenter vs. Placebo) G1: Placebo augmentation G2: aripiprazole augmentation augmentation Attrition based on mITT NA Medications Allowed Augmentation - Distribution of Ad at randomization: Escitalopram 29.6%; fluoxetine 14.2%, paroxetine 8.9%, sertraline 19.8%, venlafaxine 27.4% Strategy Other, please explain: Prospective tx phase - switch strategy; Double-blind treatement phase - augmentation strategy Parameters G1: Placebo G2: 5-20 mg/day | TRD definition; - Failed two or more adequate treatment failures (> 6 wk duration).; - OR Inadequate response to at least 1 and no more than 3 adequate AD trials (> 6 wks duration at adequate dose) prior to inclusion.; - Pts also had to establish inadequate antidepressant response in prospective treatment phase (8 wk duration); - Required a failure current episode; Tier 1 Inclusion criteria; - Outpatients 18-65 years; could understand, comply, and provide written consent.; - MDE lasting ≥ 8 wks prior to inclusion without adequat response; - At least 1, no more than 3 adequate AD trials without adequate response.; - HAM-D17 Total score ≥ 18; For continuation into double-blind tx phase HAM-D17 total score representing <50% reduction in symptoms during prospective tx phase, HAM-D17 total score ≥14; CGI-I score of ≥ 3; - Most psychotropic meds, including benzodiazepines and other hypnotics discontinued.; Exclusion criteria; - Current Axis I diagnosis of delirium, dementia, amnestic, or other cognitive disorder, panic disorder, or post traumatic stress disorder.; - Current Axix II diagnosis of borderline, antisocial, paranoid, schizoid, schizotypal, or histrionic personality disorder.; - Pts experiencing hallucinations, delusions, or any psychotic symptomatology in the current episode; - Significant substance use disorder within 12 months.; - Allergy, hypersensitivity, or previous unresponsiveness to aripiprazole.; - Participation in a clinical trial w/ aripiprazole or any other investigational product within past month; - History of thyroid pathology, neuroleptic malignant syndrome, serotonin syndrome.; - History of seizure disorder; - Postive screen for drugs of abuse; - Receipt of adjunctive antipsychotic + antidepressant for ≥ 3 wks during current episode; - Receipt of ECT for current episode; - Inadequate response to previous ECT in any episode | Subgroups NA - KQ1 Drug Study Baseline n G1: 178 G2: 184 Treatment Failure Failed 1 or more, % G1: 100.0 G2: 100.0 Failed 2 or more, % G1: 100 G2: 100 Current episode failures, mean Failed 2+ in current episode G1: 33.6 G2: 33.5 Mean failed trials NR Polarity, % Unipolar G1: 100 G2: 100 Bipolar I G1: 0 G2: 0 Bipolar II G1: 0 G2: 0 Patient Characteristics Age, mean yrs G1: 44.2 G2: 46.5 Sex, % females G1: 64.2 G2: 61.5 Race, % white G1: 92.6 G2: 87.4 Not Specified, % G1: 0 G2: 0 Right handed, % NR Groups similar at baseline Yes HAM-D 17 Baseline score, mean (SD) NR BDI Baseline score, mean (SD) NR | HAM-D (Insert #) NR BDI NR MADRS Yes G1: Placebo Augmenter G2: aripiprazole Augmenter Baseline n mITT Population G1: 172 G2: 181 Baseline score, mean (SD) G1: 25.9 (6.5) G2: 26.0 (6.1) Endpoint score, mean (SD) Calculated endpoint score G1: 20.1 (NR) G2: 17.2 (NR) Change, mean (SD) Endpoint (6wk) G1: -5.8 G2: -8.8 G1: vs. G2, P < 0.001 Week 2 G1: -3.4 G2: -6.3 G1: vs. G2, P <0.001 Responders, n Endpoint (6wk) G1: 23.8% (n = 41) G2: 33.7% (n = 61) G1: vs. G2, P = 0.027 Week 5 G1: 20.3% G2: 33.1% G1: vs. G2, P < 0.01 Week 4 G1: 15.7% G2: 30.4% G1: vs. G2, P < 0.001 Week 3 G1: 15.7% G2: 25.4% G1: vs. G2, P < 0.05 Week 2 G1: 8.1% G2: 16.6% G1: vs. G2, P < 0.05 Week 1 G1: 1.8% G2: 6.2% G1: vs. G2, P = 0.025 Remitters, n Endpoint G1: 15.7% (n = 27) G2: 26.0% (n = 47) G1: vs. G2, P = 0.011 Week 5 G1: 14.0% G2: 26.0% G1: vs. G2, P < 0.01 Week 4 G1: 11.0% G2: 22.7% G1: vs. G2, P < 0.01 Week 3 G1: 8.7% G2: 18.8% G1: vs. G2, P = 0.006 Week 2 G1: 5.8 G2: 10.5 G1: vs. G2, P = NS Week 1 G1: 1.8 G2: 3.4 G1: vs. G2, P = NS Other Response defined as ≥ 50% reduction in MADRS total score. Remission defined as response plus an absolute MADRS total score of ≤ 10. IDS G1: Placebo G2: aripiprazole[Q60] Baseline n ITT Population G1: 172 G2: 181 Baseline score, mean (SE) G1: 34.0 (1.1) G2: 34.4 (1.0) Endpoint score, mean (SE) Calculated G1: 28.8 (NR) G2: 27.4 (NR) Change, mean (SE) G1: -5.2 (0.8) G2: -7.0 (0.8) P = 0.076 **Text reports “While differences on the IDS-SR were significant at weeks 2, 3, 4, and 5, significance was not shown at endpoint” Data not shown. Responders, n NR Remitters, n NR CGI-S Baseline n mITT Population G1: 172 G2: 181 Baseline score, mean (SE) G1: 4.11 (0.05) G2: 4.08 (0.04) Endpoint score, mean (SE) Calculated G1:3.47 (NR) G2: 3.05 (NR) Change, mean (SE) Endpoint G1: -0.64 (0.08) G2: -1.03 (0.08) G1: vs. G2, P < 0.001 CGI-I Baseline n G1: 172 G2: 181 Endpoint score, mean (SE) G1: 2.81 (0.09) G2: 2.49 (0.08) G1: vs. G2, P = 0.003 Achieving 1 or 2 score, %(SD) Endpoint: G1: 37.2 G2: 53.0 G1: vs. G2, P = 0.002 Week 5: G1: 32.6 G2: 51.4 G1: vs. G2, P < 0.001 Week 4: G1: 31.4 G2: 52.5 G1: vs. G2, P < 0.001 Week 3: G1: 28.5 G2: 45.3 G1: vs. G2, P <0.001 Week 2: G1: 22.7 G2: 35.0 G1: vs. G2, P = 0.010 Week 1: G1: 12.2 G2: 18.3 G1: vs. G2, P = 0.123 Other NR | Quality of Life NR Adverse Events NA Neuropsychological or executive functioning NA Measures, Results NA Predefined NA MMSE NR Other NA Attrition Overall, % Double-blind tx phase: 10% (mITT); 11.6% (ITT) At end of treatment, % G1: 9.1% G2: 12.1% At end of followup, % NA Withdrawals due to efficacy, % G1: 1.1% G2: 1.1% Withdrawals due to adverse events, % G1: 2.3% G2: 3.3% Other Adherence/ compliance NA
Author, Year Berman, 2009^47^ Country, setting United States Multicenter Funding Bristol-Myers Squibb Co Otsuka Pharmaceutical Co Research Objective To evaluate the efficacy and safety of adjunctive aripiprazole vs. antidepressant monotherapy in pts with MDD and independently replicate the positive findings of two similar trials. Quality Rating Fair | Study design RCT Type of analysis mITT N Prospective tx phase: 827 Double-blind tx phase: 349 Duration Prospective tx phase: 8 wks Double-blind tx phase: 6 wks Primary outcome MADRS total score at endpoint 8 wks. Interventions Antidepressant + Augmenter vs. Placebo Augmenter G1: Placebo augmentation G2: aripiprazole augmentation G1: Placebo augmentation G2: aripiprazole augmentation NA Medications Allowed All pts taking an antidepressant at randomization - Distribution - Aripiprazole Group: Escitalopram: 33.9%; fluoxetine: 17.5%; paroxetine: 7.9%; Sertraline 11.9%; Venlafaxine ER: 28.8% Placebo Group: excitalopram: 30.2%; fluoxetine: 14.5%; paroxetine: 11.6%; sertraline: 17.4%; venlafaxine ER: 26.2% Strategy Augment Parameters G1: Plabebo augmentation G2: 2-20 mg/day | TRD definition Required to be in current episode Yes Tier 1 Setting(s) Not Clearly reported Inclusion criteria; - Patients 18-65 yrs of age; - DSM-IV criteria for MDE lasting ≥ 8 wks.; - Inadequate response to prior antidepressant to 1-3 antidepressant trials of ≥ 6wk duration.; - Inclusion into double-blin tx phase required meeting criteria for inadequate response score from baseline to end of prospective treatment phase, a HAM-D 17 total score of ≥ 14, and a CGI I score ≥ 3 at wks 6 and 8.; - Stable doses of hypnotics for insomnia, including benzodiazepines and other sleep aider discontinued ≥1 wk prior to prospective tx phase.; - All psychotropics prohibited.; - Txt of extrapyramidal symptoms permitted during study.; Exclusion criteria; - Current Axis I diagnosis of delirium, dementia, amnestic, or other cognitive disorder, panic disorder, or post traumatic stress disorder.; - Current Axix II diagnosis of borderline, antisocial, paranoid, schizoid, schizotypal, or histrionic personality disorder.; - Pts experiencing hallucinations, delusions, or any psychotic symptomatology in the current episode; - Significant substance use disorder within 12 months.; - Allergy, hypersensitivity, or previous unresponsiveness to aripiprazole.; - Participation in a clinical trial w/ aripiprazole or any other investigational producet within past month; - History of thyroid pathology, neuroleptic malignant syndrome, serotonin syndrome.; - History of seizure disorder.; - Postive screen for drugs of abuse.; - Receipt of adjunctive antipsychotic + antidepressant for ≥ 3 wks during current episode.; - Receipt of ECT for current episode; - Inadequate response to previous ECT in any episode | Subgroups NA - KQ1 Drug Study Baseline n G1: 172 G2: 177 Treatment Failure Failed 1 or more, % G1: 68.0 G2: 71.8 Failed 2 or more, % G1: 100.0 G2: 100.0 Current episode failures, mean Failed 2+ in current episode (%) G1: 29.1 G2: 26.6 Mean failed trials NR Polarity, % Unipolar G1: 100 G2: 100 Bipolar I G1: 0 G2: 0 Bipolar II G1: 0 G2: 0 Patient Characteristics Age, mean yrs G1: 45.6 G2: 45.1 Sex, % females G1: 68.0 G2: 78.0 Race, % white G1: 86.6 G2: 87.6 Not Specified, % NR Right handed, % NR Groups similar at baseline No - Aripiprazole group 138 females (78%) vs. Placebo 117 females (68%) HAM-D 17 Baseline score, mean (SE) G1: 20.0 (0.4) G2: 19.8 (0.4) BDI Baseline score, mean (SD) NR | N analyzed G1: 169 G2: 174 HAM-D (Insert #) Yes HAM-D17 G1: Placebo augmentation G2: aripiprazole augmentation Endpoint score, mean (SD) Calculated: G1: 14.9 (NR) G2: 12.2 (NR) Change, mean (SD) G1: -5.1 (0.6 SE) G2: -7.6 (0.6 SE) G1: vs. G2, P <0.001 Responders, n NR Remitters, n NR BDI NR MADRS Yes G1: Placebo Augmenter G2: aripiprazole Augmenter Baseline n mITT (n analyzed) G1: 169 G2: 174 Baseline score, mean (SD) G1: 27.1 (5.8) G2: 26.6 (5.8) Endpoint score, mean (SD) Calculated: G1: 20.7 (NR) G2: 16.5 (NR) Change, mean (SD) G1: -6.4 (NR) G2: -10.1 (NR) G1: vs. G2, P <0.001 Treatment difference: - 3.7 (95%CI -5.4, -2.0) Responders, n G1: 26.6% (n = 45) G2: 46.6% (n = 81) G1: vs. G2, P < 0.001 Remitters, n G1: 18.9% (n = 32) G2: 36.8% (n = 64) G1: vs. G2, P <0.001 Alternate definitions MADRS total score ≤ 12 G1: 27.2% G2: 43.7% G1: vs. G2, P < 0.001 MADRS total score ≤ 8 G1: 14.2% G2: 27.6% G1: vs. G2, P < 0.01 Other Response defined as ≥ 50% reduction in MADRS total score. Remission defined as ≤ 10 and ≥ 50% reduction in MADRS total score. Alternate Remission Definitions: MADRS total score ≤ 12; MADRS ≤ 8 IDS Yes G1: Placebo Augmenter G2: aripiprazole Augmenter[Q60] Baseline n G1: 169 G2: 174 Baseline score, mean (SE) G1: 33.0 (1.1) G2: 32.7 (1.1) Endpoint score, mean (SE) Calculated: G1: 27.6 (NR) G2: 25.8 (NR) Change, mean (SE) G1: -5.4 (1.1) G2: -6.9 (0.9) G1: vs. G2, P = 0.12 Responders, n NR Remitters, n NR CGI-S Yes G1: Placebo Augmenter G2: aripiprazole Augmenter Baseline n G1: 169 G2: 174 Baseline score, mean (SE) G1: 4.2 (0.1) G2: 4.1 (0.1) Endpoint score, mean (SE) Calculated: G1: 3.5 (NR) G2: 3.0 (NR) Change, mean (SE) G1: -0.7 (0.1) G2: -1.1 (0.1) G1: vs. G2, P <0.001 CGI-I Yes G1: Placebo Augmenter G2: aripiprazole Augmenter Baseline n G1: 169 G2: 174 Endpoint score, mean (SE) G1: 2.8 (0.1) G2: 2.4 (0.1) G1: vs. G2, P = 0.001 Achieving 1 or 2 score,%(SD) G1: NR G2: NR Other Validated measure Yes Instrument QIDS-SR Intervention G1: Placebo Augmenter G2: aripiprazole Augmenter Baseline n G1: 169 G2: 174 Baseline score, mean (SE) G1: 12.8 (0.4) G2: 13.0 (0.4) Endpoint score, mean (SE) Calculated: G1: 10.7 (NR) G2: 10.2 (NR) Change, mean (SE) G1: -2.1 (0.3) G2: -2.8 (0.3) G1: vs. G2, P = 0.08 | Quality of Life NR Adverse Events NA Neuropsychological or executive functioning NA Measures, Results NA Predefined NA MMSE NR Other NA Adequate information NA Attrition Overall, % Double-blind tx phase: 15.2% At end of treatment, % G1: 13.4 G2: 16.9 At end of followup, % NA Withdrawals due to efficacy, % G1: 1.7 G2: 1.1 Withdrawals due to adverse events, % G1: 1.7 G2: 6.2 Other Adherence/ compliance
Author, Year Corya et al., 2006^48^ Country, setting Multinational, 16 countries, 90 centers Funding Eli Lilly Research Objective: Olanzapine/fluoxetine combination (OFC) was examined in comparison with olanzapine, fluoxetine, and venlafaxine in a TRD population. Quality Rating Fair | Study design RCT Type of analysis ITT N: 483 Duration: 12 weeks Primary outcome: Change in MADRS at 12 weeks Interventions G1: Olanzapine/fluoxetine G2: Olanzapine G3: Fluoxetine G4:Venlafaxine G5: Low-dose Olanzapine/fluoxetine Parameters G1: Olanzapine/fluoxetine: Combined 4 groups G2: Olanzapine: 6 or 12 mg/d G3: Fluoxetine: 25 or 50 mg/d G4:Venlafaxine: 75-375 mg/d G5: Low-dose Olanzapine/fluoxetine: 1mg/d olanzapine, 5 mg fluoxetine Strategy Switch | TRD definition: “…documented history of a failure to achieve a satisfactory response to a selective serotonin reuptake inhibitor (SSRI) antidepressant after at least 6 weeks of therapy at a therapeutic dose” and subsequently showing less than 30% improvement after 7 weeks of venlafaxine treatment; Failure within current episode Remission defined as MADRS ≤ 8 at two consecutive visits Setting(s) Inclusion criteria: 18 years ; CGI-S 4 or greater, MDD w/o psychotic features; documented history of TRD Exclusion criteria: schizophrenia, schizoaffective disorder; other psychotic disorders, bipolar I or II disorder, PTSD, MDD w/seasonal pattern, or dissociative disorders; pregnant or nursing; concomitant medications with primary CNS activity w/ exception of benzodiazepines up to an equivalent of 4mg of lorazepam per day | Subgroups; none Treatment Failure Failed 2 or more, 100% Current episode failures, mean NR Mean failed trials Polarity, % Unipolar 100% Age, mean yrs Overall: 45.7 Sex, % females Overall: 72.5% Race, % white Overall: 89.9 Right handed, % NR and NA Groups similar at baseline Group baseline characteristics NR just overall Tier 1 | HAM-D NR MADRS Baseline n G1: 243 G2: 62 G3: 60 G4: 59 G5: 59 Baseline score, mean (SD) 30.0 (6.8) for overall sample (moderate-to-severe range) Endpoint score, mean (SD) NR Change, mean (SD) G1: -14.06 (0.59) G2: -7.71 (1.17) G3: -11.70 (1.14) G4: -13.73 (1.16) G5: -11.97 (1.13) G1: (OFC) vs. G2 (Ola), P < 0.001. all others NS Responders, n (%) G1: 100 (43.3) G2: 15 (25.4) G3: 19 (33.9) G4: 29 (50.0) G5: 20 (36.4) G! (OFC) vs. G2 (Ola), P = 0.017. all others NS Remitters (MADRS ≤ 8 for any two consecutive visits), n (%) G1: 69 (29.9) G2: 8 (13.8) G3: 10 (17.9) G4: 13 (22.4) G5: 11 (20.0) G1: (OFC) vs. G2 (Ola), P = 0.013. all others NS CGI-S Baseline n G1: 243 G2: 62 G3: 60 G4: 59 G5: 59 Baseline score, mean (SD) NR Endpoint score, mean (SD) NR Change, mean (SD) G1: -1.51 (0.07) G2: - 0.91 (0.15) G3: -1.26 (0.15) G4: -1.49 (0.14) G5: -1.23 (0.14) G1: (OFC) vs. G2 (Ola), P < 0.001. all others NS BPRS Baseline n G1: 243 G2: 62 G3: 60 G4: 59 G5: 59 Baseline score, mean (SD) NR Endpoint score, mean (SD) NR Change, mean (SD) G1: -6.01 (0.40) G2: ---3.16 (1.04) G3: -4.82 (0.88) G4: -4.76 (0.98) G5: -6.33 (0.87) G1: (OFC) vs. G2 (Ola), P = 0.008. all others NS | Quality of Life: NA Adverse Events: NA Neuropsychological or executive functioning: NA MMSE:NA Attrition: NA Adherence/ compliance: NA
Author, Year Fang et al., 2010^49^ Country, setting China - multicenter (8), both inpatient and outpatients included Funding B10th Five-year Plan[ of National Key Technologies R&D Program grants 2004BA720A21-02 (Ministry of Science and Technology of China) and the Climbing Mountain Action Plan[ Program grants 064119533 (Science and Technology Commission of Shanghai Municipality) and partly supported by National High-tech R&D Program (863 Program) grants 2006AA02Z430 (Ministry of Science and Technology of China). Research Objective Compare the efficacy and tolerability of antidepressants switch with extended-release venlafaxine (venlafaxine-XR), mirtazapine, and paroxetine in Chinese patients with MDD who had 2 consecutive unsuccessful antidepressant trials Quality Rating Fair | Study design RCT Type of analysis ITT N 150 Duration 8 weeks Interventions G1: Venlafaxine-XR 225 mg/d (n = 50) G2: Mirtazapine45 mg/d (n = 55) G3: Paroxetine20 mg/d (n = 45) Medications Allowed All patients switched to a new pharmacotherapy Strategy Switch strategy Parameters venlafaxine-XR 225 mg/d (Effexor; Wyeth, China); mirtazapine, 45 mg/d (Remeron; Organon, China); and paroxetine, 20 mg/d (Paxil; GlaxoSmithKline) | TRD definition; - Failed two or more adequate (12 weeks or more each) treatments from different classes in the current depressive episode.; - Required to be in current episode; Tier 1 Inclusion criteria; - Ages of 18 and 65 years with a diagnosis of MDD based on the criteria of the Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition and from inpatient and outpatient services; - Meet stage 2 TRD criteria described by Thase and Rush. 9 Stage 2 TRD in this study was retrospectively and/or prospectively.; Exclusion criteria; - Lifetime diagnosis of bipolar disorder, schizoaffective disorder, schizophrenia, or other psychotic disorders; - Imminent risk for suicide or homicide judged by a research psychiatrist; - Any medical contraindication to antidepressants or other psychotropic medication; - Unstable general medical condition or a condition that required combination treatment of an antidepressant and any other psychotropic medication (including typical/atypical antipsychotic agents, mood stabilizers, anticonvulsants, and stimulants); - Modified electroconvulsive therapy within 1 month of study screening; - Pregnant, planning to become pregnant, or breast-feeding | Subgroups No Baseline n G1: 50 G2: 55 G3: 45 Treatment Failure Failed 1 or more, % 100 Failed 2 or more, % 100 Current episode failures, mean NR Mean failed trials NR Polarity, % Unipolar 100 Bipolar I 0 Bipolar II 0 Patient Characteristics Age, mean yrs Overall 40.5 years Sex, % females Overall 54% Race, % white NR Not Specified, % 0 Right handed, % NR Groups similar at baseline Yes HAM-D 17 Baseline score, mean (SD) Overall 24.6 (5.8) BDI Baseline score, mean (SD) | HAM-D (17) Endpoint score, mean (SD) G1: G2: G3: Change, mean (SD) NR Responders, n G1: 32 G2: 32 G3: 30 Remitters, n G1: 21 G2: 20 G3: 21 Other There were no significant differences in the remission rates among the 3 groups (W2 = 1.097, df = 2, P = 0.578), Response Rates P = 0.664. There were also no significant differences among the groups in the cumulative proportion of remission rates at each postbaseline visit (log rank, W2 = 0.4974, df = 2, P = 0.7798). BDI NR MADRS NR IDS NR CGI-S NR CGI-I Yes G1: Venlafaxine G2: Mirtazapine G3: Paroxetine Achieving 1 or 2 score, %(SD) CGI = 1 G1: 48.0 G2: 29.1 G3: 40.0 Other P = 0.136 Other NR | Quality of Life NR Adverse Events NA Neuropsychological or executive functioning NA MMSE NR Other NR Attrition Overall, % 0.18 At end of treatment, % G1: 18.0% G2: 18.2% G3: 17.8% At end of followup, % NA Withdrawals due to efficacy, % G1: 2 G2: 6 G3: 6 Withdrawals due to adverse events, % G1: 0 G2: 0 G3: 2 Adherence/ compliance NR
Author, Year: Fava et al., 2006^50^ Country, setting: USA, Multicenter 18 primary and 23 psychiatric centers Funding: NIMH Research Objective: Compared the efficacy of switching to mirtazapine vs. nortriptyline following two prospective, consecutive, unsuccessful medication treatments for non-psychotic MDD Quality Rating: Good | Study design RCT Type of analysis ITT N: 235 Duration: 12-14 weeks Interventions G1: Mirtazapine G2: Nortriptyline Parameters G1: Mirtazapine: Up to 60mg/day G2: Nortriptyline: Up to 200mg/day Strategy: Switch Diagnosis: 100% MDD | TRD definition: 2 or more in current episode. Remission defined as HAM-D17 ≤ 7 Tier 1 Setting(s) Outpatient; Psychiatric and Primary Care Practices Inclusion criteria:; - Outpatients with a primary diagnosis of non-psychotic MDD; Exclusion criteria:; - Psychotic disorders, OCD; - Eating disorders; - General medical conditions contraindicating the use of protocol medications; - Substance dependence (only if it required inpatient detoxification); - Pregnant; - Breastfeeding.; Stable psychotropic medications allowed. Stimulant, anticonvulsant, antipsychotic mood stabilizing, nonprotocol antidepressants and potential antidepressant augmenting agents (e.g. busiprone) were not allowed. Anxiolytics (except alprazolam) and sedative hypnotics (including trazodone for sleep) | Subgroups- None Treatment Failure Failed 1 or more, 100% Failed 2 or more, 100% Current episode failures, mean Overall: 2 Failed trials, mean Overall: 2 Previous treatment, not specified, 0% Polarity, % Unipolar G1: 100 G2: 100 Bipolar I G1: 0 G2: 0 Bipolar II G1: 0 G2: 0 Age, mean yrs G1: 44.8 G2: 45.1 Sex, % females G1: 42.1 G2: 51.2 Race, % white G1: 80.7 G2: 76.0 Right handed, % NRv HAM-D 17 Baseline n G1: 114 G2: 121 Baseline score, mean (SD) G1: 19.8 (7.0) G2: 18.6 (5.9) Groups similar at baseline: Yes. More in mirtazapine 24.6% had attempted suicide vs. nortriptyline 12.4%, but this difference was controlled for in the analyses. | HAM-D 17 G1 G2: G1 G2:Endpoint score, mean (SD) G1: NR G2: NR Change, mean (SD) G1: NR G2: NR Average percentage improvement G1: NR G2: NR Responders, n G1: NR G2: NR Remitters, n G1: 14 (12.3%) G2: 24 (19.8%) G1: vs. G2, P=0.27 QIDS-SR Baseline n G1: 114 G2: 121 Baseline score, mean (SD) G1: 14.1 (5.0) G2: 14.0 (4.7) Endpoint score, mean (SD) G1: 12.6 (5.4) G2: 12.2 (5.9) Change, mean (SD): NR Average percentage improvement G1: -7.1% (35.2) G2: -10.9 (36.5) G1: vs. G2, p=0.48 Responders (50% reduction), n G1: 15 (13.4%) G2: 20 (16.5%) G1: vs. G2, p=0.57 Remitters (< 5), n G1: 9 (8.0%) G2: 15 (12.4%) | Quality of Life: NA Adverse Events: NA Neuropsychological or executive functioning: NA MMSE: NA Attrition: NA Adherence/ compliance: NA
Author, Year Mazeh et al., 2007^51^ Country, setting Israel, inpatient, single center Funding: NR Research Objective: compare the efficacy and tolerability of venlafaxine vs. paroxetine in elderly patients suffering from resistant major depression Quality Rating Fair | Study design RCT Type of analysis ITT N= 30 Duration: 6 weeks Interventions G1: Paroxetine (mean 26 mg/day) G2: Venlafaxine (165 mg/day) Parameters G1: Paroxetine: 10-60mg/d(mean 26 mg/day) G2: Venlafaxine 75-300mg/d (mean 165 mg/day) Strategy – Switch | TRD definition: “…they did not respond to two adequate pharmacological treatments for depression during this depressive episode.” Remission defined as HAM-D21 ≤ 7 Setting(s); Mental Health Center Inclusion criteria; MDD; 18 or more on Ham-D21;inpatient; ≥ 65 years old Exclusion criteria; Dementia; exposure to study drugs Diagnosis 100% MDD | Subgroups Treatment Failure NR Polarity, % Unipolar NR Age, mean yrs G1: 77.7 G2: 74.1 Sex, % females G1: 60 G2: 53 Race, % white NR Right handed, % NR Groups similar at baseline Yes Tier Tier 1 | HAM-D 21 Baseline n G1: 15 G2: 15 Baseline score, mean (SD) G1: 30.1 (7.9) G2: 26.3 (5.9) Endpoint score, mean (SD) G1: NR G2: NR Change, mean (SD) G1: -12.5 G2: -19.1 P<0.0003 Average percentage improvement G1: NR G2: NR Responders, n (%) G1: 8 (53) G2: 12 (80) P = NR Remitters, n (%) G1: 5 (33) G2: 9 (60) P = NR Data primarily reported in figures Other CGI-S Baseline n G1: 15 G2: 15 Baseline score, mean (SD) G1: 5.7 (0.9) G2: 5.5 (0.7) Change, mean G1: − 2.3 vs. G2: − 2.3 P < 0.00002 GDSBaseline n G1: 15 G2: 15 Baseline score, mean (SD) G1: 11.7 (3.0) G2:12.3 (1.5) Change, mean (SD) G1: -3.2 G2: -6.0 P<0.2 | Quality of Life: NA Adverse Events: NA Neuropsychological or executive functioning: NA MMSE: NA Attrition: NA Adherence/ compliance: NA
Author, Year McGrath et al., 2006^52^ Country, setting United StatesPrimary care and psychiatric care practice settings Funding NIMH Research Objective To compare the effectiveness and tolerability of tranylcypromine versus combination treatment with venlafaxine ER and mirtazapine in patients with treatment-resistant major depression. Quality Rating: Fair | Study design RCT Type of analysis ITT N = 109 Duration 12 -14weeks Interventions G1: Tranylcypromine G2: Venlafaxine ER + Mirtazapine Parameters G1: Tranylcypromine 10mg/d for 2wk, weekly increases of 10 mg/d until intolerance or 60 mg/d maximum G2: Venlafaxine ER + Mirtazapine: Venlafaxine 37.5 mg/d wk 1, 75 mg/d wk 2, 150 mg/d wks 3-5, 225 mg/d wks 6-8, 300 mg/d thereafter. Mirtazapine 15 mg/d wks 1-2, 30 mg/d next 8 wks, 45 mg/d thereafter Strategy - switch | TRD definition; “…didnot achieve remission with, or were intolerant of, each of the first three levels of pharmacotherapy treatment.” 3 failed treatments in current episode. Remission defined as HAM-D21 ≤ 7 Setting(s) Genera and psychiatric settings Inclusion criteria Primary diagnosis of nonpsychotic major depressive disorder by DSM-IV criteria; Did not achieve remission with or were intolerant of each of the first 3 levels of pharmacotherapy treatment in STAR*D Exclusion criteria NR Stable psychotropic medications allowed Not clearly reported | Subgroups None Treatment Failure Failed 1 or more, 100% Failed 2 or more, 100% Current episode failures, mean 3 Mean failed trials 3 Previous treatment, not specified, 0% Polarity, % Unipolar Overall; 100% Bipolar I – 0% Bipolar II – 0% Age, mean yrs G1: 46.6 G2: 45.3 Sex, % females G1: 56.9 G2: 45.1 Race, % white G1: 79.3 G2: 84.3 Right handed, % Overall NR Groups similar at baseline – Overall yes. Groups received different medications at STAR*D level 3 treatment; difference in exiting Level 3 treatment due to intolerance of treatment, but these were controlled for in analysis. Tier 1 | HAM-D 17 Baseline n G1: 58 G2: 51 Baseline score, mean (SD) G1: 19.6 (7.6) G2: 19.7 (5.5) Endpoint score, mean (SD) NR: Responders, n NR Remitters, 7 or less, n (%) G1: 4 (6.9) G2: 7 (13.7) P= NS QIDS SR Baseline score, mean (SD) G1: 13.6 (5.1) G2: 14.9 (4.1) Endpoint score, mean (SD) G1: 12.3 (5.9) G2: 11.2 (5.6) Percent change G1: -6.2 (36.9) G2: -25.0 (30.4) P = NR Response 50% or greater improvement, n (%) G1: 7 (12.1) G2: 12 (23.5) P = NS Remitters, less than 5, n (%) G1: 8 (13.8) G2: 8 (15.7) P = NS | Quality of Life: NA Adverse Events: NA Neuropsychological or executive functioning NA MMSE: NA Attrition: NA Adherence/ compliance: NA
Author, Year Poirier and Boyer, 1999^53^ Country, setting France, Multi-center Funding Wyeth-Lederle, Paris France Research Objective Compare the efficacy and safety of venlafaxine and paroxetine in patients with treatment-resistant depression. Quality Rating Fair | Study design RCT Type of analysis ITT N 123 Duration 4 weeks Interventions G1: Venlafaxine G2: Paroxetine Parameters G1: Venlafaxine initiated at 37.5 mg twice daily and increased to 200 - 300 mg/day G2: Paroxetine initiated at 20mg/day and increased to 30 – 40 mg/day Stable psychotropic medications allowed No antipsychotics or MAOIs in last month; No anti coagulants, lithium, phenytoin, mood stabilizers or ECT. Stable anxioytics could be continued. Strategy Switch Diagnosis 100% MDD | TRD definition; - Resistance to two previous successive antidepressant treatments for current episode.; - Remission defined as HAM-D17 <10; Tier 1 Setting(s) Inpatient or Outpatient; Inclusion criteria; - Inpatient or Outpatient; 18-60 years; - Major Depression < 8 months old; - HAM-D, 17 score ≥ 18; - TRD; Exclusion criteria Use of venlafaxine or paroxetine for current episode; Hypersensitive to venlafaxine or paroxetine; Use of antipsychotics or monoamine oxidase inhibitors within previous month; Use of anticoagulants, lithium, phenytoin, mood stabilizers, or ECT; Anxioytics could continue if taken at stable dose one month prior and continued through study; Mental disorder other than affective disorder; Suicidal ideation; Organic disease known as factor in TRD; Seizure disorders; Alcohol or drug dependence; Cardiac, renal, or hepatic disease; Pregnant; Breastfeeding; Women not using acceptable form of contraception | Subgroups None Treatment Failure Failed 1 or more, % 100 Failed 2 or more, % 100 Current episode failures, mean NR Mean failed trials NR Previous treatment, not specified, % NR Polarity, % Unipolar NR Bipolar I NR Bipolar II NR Age, mean yrs G1: 42.5 G2: 44.1 Sex, % females G1: 74 G2: 70 P = 0.59 Race, % white NR Right handed, % NR HAM-D 17 Baseline n G1: 61 (LOCF), 52 (OC) G2: 62 (LOCF), 55 (OC) Baseline score, mean (SD) G1: 24.6 (3.9) G2: 24.5 (4.1) Groups similar at baseline Yes | HAM-D 17 Endpoint score, calculated G1: 13.5 [OC] G2: 14.3 [OC] Change, mean (SD) G1: -11.1 (8.5) [OC] G2: -10.2 (6.8) [OC] OC, P= 0.55 ITT, P = 0.70 Average improvement NR Responders, n G1: 27 (44.3%) G2: 18 (29.0%) OC, P = 0.044 LOCF, P = 0.07 emitters, n G1: 22 (36.1%) G2: 11 (17.7%) OC, P = 0.01 ITT, P = 0.02 Other BDI NR MADRS NR IDS NR CGI-S NR CGI-I Baseline n G1: 61 (LOCF), 52 (OC) G2: 62 (LOCF), 55 (OC) Average percentage improvement G1: 73% [OC] G2: 84% [OC] P = 0.39 Proportion of patients achieving a score of 1 or 2, n (%) G1: 33 (64) [OC] G2: 36 (66) [OC] P = NS LOCF results “look similar” | Quality of Life NA Adverse Events NA Neuropsychological or executive functioning NA MMSE NA Attrition NA Adherence/ compliance NA
Author, Year Shelton et al., 2005^54^ Country, setting United States and Canada, multicenter (71 sites) Funding Eli Lilly and Company Research Objective To replicate findings within a larger patient sample, hypothesizing that olanzapine/fluoxetine combination would produce greater reductions in depressive symptoms than other treatment groups. Quality Rating Good | Study design RCT Type of analysis Mixed-effects model repeated-measures regression N 500 Duration 8 Weeks Interventions G1Olanzapine/fluoxetine combination G2: Olanzapine monotherapy G3: Fluoxetine monotherapy G4: Nortriptyline Parameters Olanzapine/fluoxetine combination = 25mg/d fluoxetine and 6mg/d olanzapine OR 50mg/d fluoxetine and 12mg/d olanzapine; Mean modal doses (SD) = 8.5 (3.1) olanzapine plus fluoxetine 35.6 (12.7) Olanzapine monotherapy = 6-12mg/d; Mean modal dose (SD)= 8.3(3.1) Fluoxetine monotherapy= 25-50mg/d; Mean modal dose (SD) = 35.8 (12.8) Nortriptyline = 25-175mg/d Mean modal dose (SD) = 103.5 (33.9) Strategy Switch | TRD definition ≥ 1 past treatment failure to an SSRI after ≥ 4 weeks of therapy at a therapeutic dose. Failure was not required to be in current episode; and treatment failure during a 7 week nortriptyline dose-escalation lead-in period. So, 2 failed treatments (one in current episode) Failure defined as < 30% improvement in MADRS total score from baseline. Treatment response ≥ 50% decrease from baseline to endpoint in MADRS total score. Remission = 2 consecutive MADRS total scores ≤ 8. Tier 1 Setting(s) NR Inclusion criteria Unipolar, nonpsychotic MDD Treatment failure as described above. MADRS total score ≥ 20 at both beginning and end of screening period. Exclusion criteria Concomitant medication with primary central nervous system activity were not allowed with the exception of lorazepam. No other benzodiazepines were permitted. Patients developing psychotic symptoms during lead-in phase. Pregnant; Lactating; ECT treatment within 1 month or likely to require ECT during the study. | Subgroups Patients with an SSRI treatment failure during the current MDD episode. Treatment Failure Failed 1 or more, % 100 Failed 2 or more, % 100 Current episode failures, mean NR Mean failed trials NR Previous treatment, not specified, % NR Polarity, % Unipolar G1100 G2:100 G3:100 G4: 100 Bipolar I G10 G2:0 G3:0 G4: 0 Bipolar II G10 G2:0 G3:0 G4: 0 Age, mean yrs G142.5 G2:43.4 G3:41.7 G4:41.5 Sex, % females G167.1 G2:64.6 G3:72.5 G4: 67.6 Race, % white G190.4 G2:82.6 G3:90.8 G4: 88.2 Right handed, % G1NR G2:NR G3:NR G4:NR Groups similar at baseline Yes | HAM-D 21 NR BDI NR MADRS Baseline n G1: 146 G2: 144 G3: 142 G4: 68 Baseline score, mean (SD) G1: 28.5 (7.5) G2: 28.4 (7.3) G3: 28.4 (7.3) G4: 28.8 (6.5) Week 0.5 Endpoint score, calculated G1: 24.87 G2: 24.62 G3: 25.88 G4: 25.85 Change, mean (SE) G1: -3.63 (0.65) G2: -3.78 (0.65); vs. G1: P = 0.868 G3: -2.52 (0.66); vs. G1: P = 0.230 G4: -2.95 (0.94); vs. G1: P = 0.555 Week 1 Endpoint score, calculated G1: 21.6 G2: 23.2 G3: 23.23 G4: 25.02 Change, mean (SE) G1: -6.90 (0.65) G2: -5.20 (0.65); vs. G1: P = 0.063 G3: -5.17 (0.66); vs. G1: P = 0.061 G4: -3.78 (0.95); vs. G1: P = 0.007 Week 2 Endpoint score, calculated G1: 19.51 G2: 21.42 G3: 22.72 G4: 24.10 Change, mean (SE) G1: -8.99 (0.65) G2: -6.98 (0.65); vs. G1: P = 0.029 G3: -5.68 (0.66); vs. G1: P < 0.001 G4: -4.70 (0.95); vs. G1: P < 0.001 Week 3 Endpoint score, calculated G1: 19.28 G2: 20.85 G3: 22.30 G4: 23.47 Change, mean (SE) G1: -9.22 (0.65) G2: -7.55 (0.66); vs. G1: P=0.071 G3: -6.10 (0.67); vs. G1: P < 0.001 G4: -5.33 (0.95); vs. G1: P < 0.001 Week 4 Endpoint score, calculated G1: 18.56 G2: 20.54 G3: 21.56 G4: 22.84 Change, mean (SD) G1: -9.94 (0.66) G2: -7.86 (0.66); vs. G1: P = 0.026 G3: -6.84 (0.68); vs. G1: P = 0.001 G4: -5.96 (0.95); vs. G1: P <0.001 Week 5 Endpoint score, calculated G1: 19.50 G2: 21.18 G3: 21.27 G4: 21.33 Change, mean (SE) G1: -9.00 (0.67) G2: -7.22 (0.67); vs. G1: P = 0.061 G3: -7.13 (0.68); vs. G1: P = 0.050 G4: -7.47 (0.95); vs. G1: P = 0.190 Week 6 Endpoint score, calculated G1: 19.14 G2: 21.00 G3: 20.31 G4: 20.25 Change, mean (SE) G1: -9.36 (0.68) G2: -7.40 (0.69); vs. G1: P = 0.043 G3: -8.09 (0.69); vs. G1: P = 0.191 G4: -8.55 (0.96); vs. G1: P = 0.491 Week 7 Endpoint score, calculated G1: 19.59 G2: 21.54 G3: 20.49 G4: 20.18 Change, mean (SE) G1: -8.91 (0.69) G2: -6.86 (0.70); vs. G1: P = 0.036 G3: -7.91 (0.70); vs. G1: P = 0.305 G4: -8.62 (0.97); vs. G1: P = 0.805 Week 8 Endpoint score, calculated G1: 19.79 G2: 21.45 G3: 19.89 G4: 21.34 Change, mean (SE) G1: -8.71 (0.70) G2: -6.95 (0.71); vs. G1: P = 0.77 G3: -8.51 (0.70); vs. G1: P = 0.841 G4: -7.46 (0.98); vs. G1: P = 0.298 Average percentage improvement NR Responders, n [calculated] (%, as reported in text) G1: 40 (27.5) G2: 27 (19.3) G3: 41 (28.9) G4: 20 (30.3) P = 0.18 Remitters, n [calculated] (%, as reported in text) G1: 24 (16.9) G2: 18 (12.9) G3: 18 (13.3) G4: 12 (18.2) P = 0.62 ** Of the 72 pts who remitted, 7 relapsed; No significant difference between groups P =0.21 Other: Post hoc Subgroup Analysis of pts with treatment failure during current MDD episode N=314 Significant main effects for treatment (P = 0.004), for visit (P < 0.001), and for treatment-by-visit interaction (P = 0.04). Endpoint score, calculated G119.4 G2: 22.8 G3: 21.3 G4: 20.9 Change, mean G1: -9.1 G2: -5.6; vs. G1: P = 0.005 G3: -7.1; vs. G1: P = 0.18 G4: -7.9; vs. G1: P = 0.33 IDS NR CGI-S Baseline n G1: 146 G2: 144 G3: 142 G4: 68 Baseline score, mean (SE) G1: 4.4 (0.1) G2: 4.3 (0.1) G3: 4.3 (0.1) G4: 4.4 (0.1) Endpoint score, calculated G1: 3.4 G2: 3.7 G3: 3.6 G4: 3.7 Change, mean (SE) G1: -1.0 (0.1) G2: -0.6 (0.1 G3: -0.7 (0.1) G4: -0.7 (0.1) P-Values: Overall: P = 0.048 G1: vs. G2: P = 0.006 G1: vs. G3: P = 0.088 G1: vs. G4: P = 0.131 CGI-I NR | Quality of Life NA Adverse Events NA Neuropsychological or executive functioning NA MMSE NA Attrition NA Adherence/ compliance NA
Author, Year Shelton et al., 2005^54^ Country, setting NR, outpatient setting Funding NR Research Objective: To assess the efficacy and safety of olanzapine combined with fluoxetine versus either agent alone in patients with recurrent major depressive disorder who were unresponsive to conventional antidepressant therapy. Quality Rating – Good | Study design RCT Type of analysis ITT N = 28 Duration 8 weeks Interventions G1: Olanzapine + placebo (OLA) G2: Fluoxetine + placebo (FLU) G3: Olanzapine + fluoxetine (COMBO) Parameters G1: Olanzapine + placebo (OLA): 5-20 mg/d G2: Fluoxetine + placebo (FLU): 20-60mg/d G3: Olanzapine + fluoxetine (COMBO): same dose as above Strategy – Augment (add OLA to FLU) or switch (to OLA) | TRD definition Failure “…history of failure to respond to antidepressants of two different classes, one of which was not an SSRI, after at least 4 weeks of therapy at an acceptable therapeutic dose. Failure to respond was confirmed prospectively during a screening period in which fluoxetine was given.”; ≥ 2 Tier 1 Setting(s) Outpatient Inclusion criteria; - Met DSM-IV criteria for recurrent major depression without psychotic features; - Resistant to conventional antidepressant pharmacotherapy; - Score of greater to or equal to 20 on the HRSD-21; Exclusion criteria; - History of psychosis, dysthymic disorder, or bipolar disorder | Subgroups - None Treatment Failure Failed 1 or more, 100% Failed 2 or more, 100% Current episode failures, mean NR Mean failed trials Previous treatment, not specified, 0% Polarity, % Unipolar 100% Age, mean yrs - 42: Sex, % females - 75 Race, % white - 96 Groups similar at baseline Unclear; only #'s are reported HAM-D 21 Baseline n G1: (OLA): 8 G2 (FLU): 10 G3 (COMBO):10 Mean baseline severity not reported, but eligibilty criteria required that 21-item HAM-D was ≥ 20, | HAM-D 21 Change, mean (SD) G1: -5.9 G2: -3.8 G3:-11.7 G3 vs. G1, P = 0.03 G3 vs. G2 (P = 0.07) MADRS Baseline n G1: 8 G2: 10 G3:10 Change, mean (SD) G1: -2.8 G2: -1.2 G3:-13.6 Responders, n (%) G1: 0 (0) G2: 1 (10) G3:6 (60) G3 vs. G1, P = 0.03 G3vs. G2, P = 0.11 | Quality of Life: NA Adverse Events: NA Neuropsychological or executive functioning: NA MMSE: NA Attrition: NA Adherence/ compliance: NA
Author, Year Thase, 2007^55^ Country, setting United States and Canada Funding Eli Lilly and Co. Research Objective Examine the efficacy and tolerability of olanzapine/fluoxetine combination, olanzapine and fluoxetine in outpatients with 2 treatment failures during the current mood episode. Quality Rating Fair | Study design RCT; 2 identical concurrent studies; sites were randomly assigned to either Study 1 or Study 2. Type of analysis ITT N 605 Duration 8 weeks Interventions G1: Olanzapine/Fluoxetine Combination G2:Fluoxetine G3: Olanzapine Parameters G1: Olanzapine 6, 12, or 18 mg/day + 50 mg/day fluoxetine G2: Olanzapine 6, 12, or 18 mg/day G3: Fluoxetine 50 mg/day Strategy Switch | TRD definition “Failure to achieve satisfactory response to an antidepressant (except fluoxetine) after at least 6 weeks at a therapeutic dose occurring within the current episode of MDD.” Second failure occurred during, “an 8-week open-label lead-in phase to establish fluoxetine resistance.” Setting(s) Outpatient Inclusion criteria 18-65 years; HAM-D17 ≥ 22; Diagnosis of MDD, recurrent, without psychotic features; Failure to 6 week antidepressant therapy within current episode of MDD; Failure to exhibit response to fluoxetine during 8 week lead-in phase. Exclusion criteria Schizophrenia; Schizoaffective disorder; Psychotic disorders, Bipolar disorder; Posttraumatic stress disorder; Dissociative disorders; Pregnant; Breast0feeding; Postpartum depression; MDD with atypical features; MDD with seasonal pattern; Paranoid, schizoid, schizotypal, antisocial, severe borderline personality disorder; Significant medical illness; Concomitant medications with primary central nervous system activity Interim Exclusion Criteria: Response to fluoxetine during lead in prior to randomization or presentation of psychotic features. | Subgroups None Treatment Failure Failed 1 or more, % 100% Failed 2 or more, % 100% Current episode failures, mean NR Mean failed trials NR Previous treatment, not specified, % NR Polarity, % Unipolar G1100% G2:100% G3:100% Bipolar I G2: 0 G3: 0 G1: 0 Bipolar II G1: 0 G2: 0 G3:0 Age, mean yrs Study 1 G1: 43.3 G2: 44.8 G3: 45.7 Study 2 G1: 45.3 G2: 44.5 G3: 43.0 Pooled G1: 44.3 G2: 44.6 G3: 44.3 Sex, % females Study 1 G1: 61.8 G2: 58.7 G3: 58.3 Study 2 G1: 70.4 G2: 65.7 G3: 65.0 Pooled G1: 66.0 G2: 62.1 G3: 61..8 Race, % white Study 1 G1: 85.3 G2: 83.7 G3: 76.0 Study 2 G1: 91.8 G2: 88.2 G3: 88.3 Pooled G1: 88.5 G2: 85.9 G3: 82.4 Right handed, % G1: NR G2: NR G3:NR Groups similar at baseline Yes Tier Tier 1 | HAM-D 21 NR BDI NR MADRS Baseline n (both studies combined) G1: 200 G2: 206 G3:200 Study1 Baseline score, mean (SD) G1: 29.5 (7.1) G2: 29.7 (6.9) G3: 29.7 (7.1) Study 2 Baseline score, mean (SD) G1: 30.6 (6.1) G2: 30.1 (5.9) G3: 30.1 (6.3) Pooled Baseline score, mean (SD) G1: 30.0 (6.7) G2: 29.9 (6.4) G3: 29.9 (6.7) Study1 Endpoint score, calculated G1: 18.7 G2: 20.3 G3: 19.6 Study2 Endpoint score, calculated G1: 16.0 G2: 21.1 G3: 22.4 Pooled Endpoint score, calculated G1: 17.4 G2: 20.7 G3: 21 Study 1 Change, mean (SD) G1: -10.8 (10.0) G2: -9.4 (9.9) G3:-10.1 (9.6) P-values: Overall, P = 0.640 G1: vs. G2, P = 0.346 G1: vs. G3, P = 0.624 Study 2 Change, mean (SD) G1: -14.6 (10.2) G2: -9.0 (9.5) G3: -7.7 (8.2) P-values: Overall, P < 0.001 G1: vs. G2, P < 0.001 G1: vs. G3, P < 0.001 Pooled Change, mean (SD) G1: -12.6 (10.3) G2: -9.2 (9.7) G3: -8.9 (9.0) P-values: Overall, P < 0.001 G1: vs. G2, P < 0.001 G1: vs. G3, P < 0.001 Study 1 Responders, n (%) G1: 37 (36.6) G2: 30 (29.4) G3: 34 (35.8) Overall P = 0.496 Study 2 Responders, n (%) G1: 43 (44.3) G2: 30 (29.7) G3: 17 (16.7) Overall P <0.001 Pooled Responders, n (%) G1: 80 (40.4) G2: 60 (29.6) G3: 51 (25.9) Overall P = 0.006 G1: vs. G2, P = 0.028 G1: vs. G3, P = 0.003 Study1 Remitters, n (%) G1: 24 (23.8) G2: 18 (17.6) G3: 18 (18.9) Overall P = 0.522 Study 2 Remitters, n (%) G1: 30 (30.9) G2: 16 (15.8) G3: 11 (10.8) Overall P = 0.001 Pooled Remitters, n (%) G1: 54 (27.3) G2: 34 (16.7) G3: 29 (14.7) Overall P = 0.004 G1: vs. G2, P = 0.012 G1: vs. G3, P = 0.003 Other IDS CGI-S Baseline n (both studies combined) G1: 200 G2: 206 G3:199 Study 1 Baseline score, mean (SD) G14.5 (0.7) G2: 4.7 (0.7) G3: 4.6 (0.7) Study 2 Baseline score, mean (SD) G1: 4.7 (0.7) G2:4.7 (0.7) G3: 4.7 (0.7) Pooled Baseline score, mean (SD) G1: 4.6 (0.7) G2: 4.7 (0.7) G3: 4.7 (0.7) Study 1 Endpoint score, calculated G1: 3.4 G2: 3.7 G3: 3.5 Study 2 Endpoint score, calculated G1: 3.2 G2: 3.6 G3: 3.9 Pooled Endpoint score, mean (SD) G1: 3.3 G2: 3.7 G3: 3.8 Study 1 Change, mean (SD) G1: -1.1 (1.3) G2: -1.0 (1.2) G3:-1.1 (1.1) Overall, P = 0.681 G1: vs. G2, P = 0.384 G1: vs. G3, P = 0.722 Study 2 Change, mean (SD) G1: -1.5 (1.3) G2: -1.1 (1.2) G3: -0.8 (1.1) Overall, P < 0.001 G1: vs. G2, P = 0.004 G1: vs. G3, P < 0.001 Pooled Change, mean (SD) G1: -1.3 (1.4) G2: -1.0 (1.2) G3: -0.9 (1.1) Overall, P = 0.003 G1: vs. G2, P = 0.008 G1: vs. G3, P = 0.001 CGI-I NR Brief Psychiatric Rating Scale (BPRS) Baseline n (both studies combined) G1: 200 G2: 206 G3:199 Study 1 Baseline score, mean (SD) G1: 17.1 (7.7) G2: 17.6 (7.7) G3: 16.1 (6.5) Study 2 Baseline score, mean (SD) G1: 15.2 (5.7) G2: 15.3 (5.6) G3: 14.8 (5.5) Pooled Baseline score, mean (SD) G1: 16.2 (6.8) G2: 16.5 (6.8) G3: 15.4 (6.0) Study 1 Endpoint score, calculated G1: 11.7 G2: 12.8 G3: 11.8 Study 2 Endpoint score, calculated G1: 9.3 G2: 11.0 G3: 12.4 Pooled Endpoint score, calculated G1: 10.6 G2: 11.9 G3: 12.1 Study 1 Change, mean (SD) G1-5.4 (7.5) G2: -4.8 (7.7) G3: -4.3 (7.4) Overall, P = 0.646 G1: vs. G2, P = 0.562 G1: vs. G3, P = 0.357 Study 2 Change, mean (SD) G1: -5.9 (6.8) G2: -4.3 (6.1) G3: -2.4 (6.2) Overall, P = 0.001 G1: vs. G2, P = 0.058 G1: vs. G3, P < 0.001 Pooled Change, mean (SD) G1: -5.6 (7.2) G2: -4.6 (7.0) G3:-3.3 (6.8) Overall, P = 0.009 G1: vs. G2, P = 0.097 G1: vs. G3, P = 0.002 | Quality of Life NA Adverse Events NA Neuropsychological or executive functioning NA MMSE NA Attrition NA Adherence/ compliance NA

Evidence Table 9 KQ 2 – Tier 1: Maintaining remission or treating patients with unresponsive or recurrent disease

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Avery et al., 2006^10^ Avery 2007^11^ Country, setting USA, Single center, University department of psychiatry, outpatient Funding NIMH Research Objective To test hypothesis that patients receiving active TMS would show a greater antidepressant response rate than those receiving sham stimulation Quality Rating Good Fair for KQ2 and subgroups11 (small number of people followed for relapse; used a single measure and did not account for additional medical conditions) | Study design RCT Type of analysis ITT N 68 Duration 4 weeks (15 sessions) of txt, primary assessment 1 week after completion of txts. Responders were evaluated for relapse 2 wks after primary endpoint Interventions G1: High-left rTMS G2: Sham Medications Allowed; - Pts encouraged, although not required, to discontinue current antidepressant medication, sedatives, or benzodiazepines; (continuing AD medication G1: 31% vs. G2: 27%; continuing benzodiazapines G1: 26% vs. G2: 24%); - Those stopping medications had to be medication-free for at least 2 weeks; - All responders given AD post rTMS treatment (active or sham); Strategy Mixed-within group differences Parameters rTMS; - Frequency (Hz):10; - Motor threshold (%): 110; - Number of trains: 32; - Length of train (seconds): 5; - Inter-train interval: 25-30; - Pulses per session: 1600; - Total number of sessions: 15 in 4 wks; Sham; - Identical stimulation parameters; - Lateral edgeof coil rotated 90° away from scalp | TRD definition; - Failed to respond to or unable to tolerate at least 2+ adequate AD trials (defined by score ≥3 on ATHF); - Failures not required to be in current episode; Tier 1 Inclusion criteria; - TRD; - 21 to 65 years old; - DSM-IV criteria for current major depressive disorder (MDD); - HAM-D 17 ≥ 17 and a decrease of no more than 20% between screening and 1st txt day; Exclusion criteria; - Previous rTMS exposure; - bipolar disorder,; - previous failure of nine or more bitemporal ECT treatments; - current major depressive episode longer than 5 years; - history of substance abuse or dependence withinpast 2 years,; - antisocial or borderline personality disorder,; - active suicidal ideation; - current symptoms of psychosis,; - Hx of seizure disorder,; - Hx of closed head injury with loss of consciousness or prior brain surgery; - any other major psychiatric or medical comorbidity | Subgroups Pain, subgroup analysis presented in Avery et al, 2007^11^ Baseline n G1: 35 G2: 33 Treatment Failure Current episode failures, mean (SD) G1: 1.46 (0.78) G2: 1.48 (0.67) Mean failed trials (SD) G1: 3.2 (2.44) G2: 3.3 (1.72) Polarity, % Unipolar 100 Age, mean yrs G1: 44.3 G2: 44.2 Sex, % females G1: 60 G2: 52 Race, % white NR Right handed, % NR Groups similar at baseline Yes HAM-D 17 Baseline score, mean (SD) G1: 23.5 (3.9) G2: 23.5 (2.9) BDI Baseline score, mean (SD) G1: 28.1 (8.7) G2: 28.4 (8.0) | HAM-D 17 Endpoint score, mean (SD) G1: 15.7 G2: 19.8 Change, mean (SD) G1: -7.8 (7.8) G2: -3.7 (6.3) Group × time P = 0.002 Responders, n G1: 11 (31.4%) G2: 2 (6.1%) P = 0.008 Remitters, n HAM-D21 < 10 G1: 7 (20.0%) G2: 1 (3.0%) P = 0.033 HAM-D 17 6- month relapse, n (%) G1: 6 (54.5); 1 lost to follow up G2: 1 (50); 1 lost to follow up P= NR G1 G2:BDI Change, mean (SD) G1: 11.3 (12.8) G2: 4.8 (8.5) Random Regression analyses revealed significant group by time interaction (P = 0.003) | Quality of Life NR Adverse Events Overall, % NR Site pain first session sham none (0/33) vs. TMS group, 41% (14/35)15th session sham 3% (1/30) vs. TMS 33% (11/33). The discomfort pain scale ratings (0-4) decreased inTMS group in subsequent treatment sessions, decreasing from a mean of 1.89 (1.02) at session 1 to 1.11 (1.03) at session 15 (t = 4.24, P < 0.001). Changes from baseline in128 individual SAFTEE scores -emerging symptoms were analyzed by chi-square analyses at visits 5, 10, 15, and 16 with a Bonferroni correction, there were no significant differences between TMS and sham in any ofemerging symptoms. (Data = NR) Neuropsychological or executive functioning No sig differences in GOAT, RAVLT, WAIS-R, COWAT, and SAFTEE; SUBGROUP ANALYSIS11: At 15th session pain TMS 33% vs, sham 3% (P < 0.05) No statistically significant (P > 0.05) time by treatment group interactions for any of neuropsychological test measures.models were refit withoutinteraction term, there was no significant treatment group main effect (P > 0.05) evident for any ofneuropsychological tests, indicatinggroups had similar levels of neuropsychological performance collapsed over time. Several measures showed significant main effects of time, that is, collapsed over groups, there was significant improvement in individual neuropsychological test performances for both groups. No confusion was associated withTMS treatments.GOAT assessments were well within normal range and ranged from 98 to 100. No significant (P > 0.05) differences between groups for any session. MMSE NR Attrition Overall, % 7.4% (5/68) At end of treatment, % NR At end of follow-up, % NR Withdrawals due to efficacy, % G1: 0 G2: 3.0 Withdrawals due to adverse events, % G1: 0 G2: NR Very unclear as to when patients discontinued Adherence/ compliance NR
Author, Year Boutros et al., 2002^13^ Country, setting US, Yale School of Medicine and VA-Connecticut, outpatient Funding VA Merit Award & K24 DA00520-01A1/DA/NIDA NIH HHS; 1 author employee of Pfizer Research Objective To provide additional data on effiacy and safety for rTMS as an augment strategy in TRD Quality Rating Fair | Study design RCT Type of analysis ITT N 21 Duration 2 weeks txt; follow-up with responders for up to 20 weeks post txt Interventions G1: rTMS G2: Sham Medications Allowed; - Pts allowed to continue all current psychotropic meds; Strategy Augmentation, 3 pts in active and 1 in sham txt were not on any meds Parameters rTMS:; - Frequency (Hz):20; - Motor threshold (%): 80; - Number of trains: 20; - Length of train (seconds): 2; - Inter-train interval: 58; - Pulses per session: 800; - Total number of sessions: 10 over 10 weekdays; Sham:; - Coil angled 90 degrees to scalp; - 1 wing of figure 8 touching scalp | TRD definition; - 2+ failed trials of adequate dose and durations; - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - Major Depression; - HAM-D25 >= 20; Exclusion criteria; - Suicidality; - “Prominent” psychotic sympotms; - History of neurological disorders; - current drug abuse | Treatment Failure Mean failed trials NR Polarity, % Unipolar Overall: 100% Age, mean yrs G1: 49.5 G2: 52.0 Sex, % females G1: 25 G2: 10 Right handed, % G1: 90.9 G2: 88.9 HAM-D Baseline n G1: 12 G2: 9 Baseline score, mean (SD) G1: 34.4 (10.1) G2: 31.7 (4.9) | HAM-D 25 Endpoint score, mean (SD) At 2 weeks G1: 29.0 G2: 28.11 Change, mean (SD) G1: -11.75 G2: -6.22 P = NS Responders, n Defined as 30% improvement on Ham-D 25 G1: 7 G2: 2 Responders, n (%) Defined as 50% improvement on Ham-D 25 G1: 3 G2: 2 Relapse Defined as ≥ baseline score ± 10% Of 6 active treatment responders inluded in 20-week follow-up (no continuing intervention), 4 relapsed. Of 1 sham responder included in the 20-week follow-up, 1 relapsed. | Quality of Life NR Adverse Events Overall, % G1: (% of pts reporting AEs) 66.7 G2: 55.6 Cognitive impairment, % Difficulty concentrating (phase 1 only) G1: 25 G2: NR Headache, % “most frequent complaint” % NR Other:; - scalp tenderness at site of stimulation: 25%, 11.1%; - hearing problem: 8.3%, NR;; - diarrhea: 8.3%, NR; Attrition Overall, % 18.2% (4/22) At end of treatment, % G1: 8.3 (1/12) G2: 30.0 (3/10) At end of follow-up, % NR Withdrawals due to efficacy, %: NR Withdrawals due to adverse events, %: NR Adherence/ compliance NR

Evidence Table 10 KQ 2 – Tier 2: Maintaining remission or treating patients with unresponsive or recurrent disease

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Berman et al., 2000^28^ Country, setting US, urban community health center, inpatient and outpatients Funding Veterans Administration, NIMH, State of CT Research Objective To assessefficacy of rTMS in unmedicated TRD patients Quality Rating Fair | Study design RCT Type of analysis ITT N 20 Duration 2 weeks (10 weekdaysof txt) Primary outcome = HAM-D 25 at 2 wks Interventions G1: rTMS G2: Sham rTMS Medications Allowed All patients free of antidepressants, neuroleptics, and benzodiazepines Inpatients pts allowed chloral hydrate for sleep Strategy Switch Parameters rTMS – LDLPFC; - Frequency (Hz): 20; - Motor threshold (%): 80; - Number of trains: 20; - Length of train (seconds): 2; - Inter-train interval:58; - Pulses per session:800; - Total number of sessions: 10 in 10 days; Sham; - Paddle angled approximately 30 – 45 degrees off of scalp with bottom coil margin elevated approximately one-half cm from scalp and lucite paddle casing firmly applied against the scalp | TRD definition; - 1+ failed trials (4+ weeks duration with at least 200 mg mg/d of imiprimine, 20mg/day fluoxetine, 60mg/d phenelzine, 225mg/d venlafaxine, 30mg/d mirtazapine); - Not required to be in current episode; Tier 2 Inclusion criteria; - Current Major depressive episode (perHAM-D); Exclusion criteria; - Hx of sig. neurological illness; - EEG abnormalities suggestive of an epileptic predisposition; - Substance or alcohol use abuse diagnosis,; - Sig. unstable medical illness,; - Females - pregnancy or inadequate birth control | Treatment Failure Current episode failures, mean G1: 5 G2: 3.5 (+ a median of 1 aumgmentation in eachgroup) Polarity, % Unipolar G1: 100 G2: 90 Bipolar II G1: 0 G2: 10 Age, mean yrs G1: 45.2 G2: 39.4 Sex, % females G1: 20 G2: 40 Race, % white G1: 100 (n=1 hispanic) G2: 100 (n=1 hispanic) HAM-D 25 Baseline n G1: 10 G2: 10 Baseline score, mean (SD) G1: 37.1 G2: 37.3 | HAM-D 25 G1: rTMS G2: Sham TMS Endpoint score, mean (SD) At week 2 G1: 24.6 G2: 36.4 *Adjusted Change (based on best fit slopes), mean (SEM) G1: -14.0 (3.7) G2: -0.2 (4.1) P < 0.05 Responders, n 50% decrease from baseline and score ≤, 15 G1: 1 (10) G2: 0 P = 0.09 2-month maintained response, n % G1: 1 (100) G2: 0 (100) P=NR Three partial responders symptom severity returned to baseline within 1-2 weeks BDI Change, mean (SD) G1: 11.4 (5) G2: 4.7 (6) P = 0.27\\\ | Quality of Life NR Adverse Events Headache, n G1: 60 G2: 50 Difficulty starting urination great in active group P = 0.03 Remaining 21 potential side effects assessed by the SECL were not significantly different between groups after correction for multiple comparisons (data NR) Poor memory, nausea or vomiting, constipation, drowsiness, blurred vision, increased appetite, dry mouth, decreased appétit, tremors and shakiness, nightmares, difficulty sitting still, trouble concentrating, irregular or pounding heartbeat, diarrhea, frequent need to urinate, rash, ringing in the ears, sweating, faintness or lightheadedness, poor coordination, and muscle stiffness MMSE NR Attrition Overall, % 15 At end of treatment, % G1: 0.0 G2: 30.0 At end of follow-up, % G1: NA G2: NA Withdrawals due to efficacy, % G1: 0 G2: 30 Withdrawals due to adverse events, % G1: 0 G2: 0 Adherence/ compliance NR
Author, Year O'Reardon, 2007^31^ Janicak, 2007^56,*^ Sovason, 2007^57^ Janicak 2010^58^ Country, setting US, Canada, Australia; multicenter, outpatient/inpatient status not clearly reported Funding Neuronetics Research Objective To test whether transcranial magnetic stimulation (TMS) overleft dorsolateral perfrontal cortex is effective and safe inacute treatment of major depression and to determine whether the benefit of TMS dissipates over a clinically meanignful duration of follow-up Quality Rating Good | Study design RCT Type of analysis Modified ITT (m-itt) N 325 randomized; Continuation of 67 responders from original 301 patientsincluded in final analysis; 99 with rTMS response compared with 21 sham responders in durability study Duration 6 weeks; Primary efficacy outcome (MADRS) collected at wk4. Sham patients could cross over after 4 weeks if not responding. 24 weeks; open-label continuation of effect study Interventions G1: Active TMS G2: Sham TMS Medications Allowed All patients were free of ADs and other psychotropic medications directed at treating depression. Pts allowed only limited use hypnotics, anxiolytics for txt emergent insomnia or anxiety Strategy Switch Parameters rTMS; - Frequency (Hz): 10; - Motor threshold (%): 120; - Number of trains: 75; - Length of train (seconds): 4; - Inter-train interval: 26; - Pulses per session: 3000; - Total number of sessions: 5/week for 4-6 wks; For add-on rescue treatment 2/week for 2wks then 5/week for 4wks; rTMS Sham:; - Coil has embedded magnetic shield, limiting magnetic energy reaching cortex to 10% or less than active coil | TRD definition; - Specifically required to have failed at least one in this or most recent episode OR four failed attempts in a lifetime; Tier 2 Setting(s) Not clearly reported Inclusion criteria; - Aged 18—70; - DSM-IV diagnosis of MDD; - Single episode or recurrent, with a current episode duration ≤3; - CGI-S score ≥ 4; - HAM-D17 ≥ 20 Symptom stability during a 1-week no-treatment lead-in period, with a HAM-D17 total score of at least 18 and a decrease in score of 25% or less from that observed atscreening assessment; Exclusion criteria; - A lifetime history of psychosis, bipolar disorder, or obsessive-compulsive disorder; - Posttraumatic stress disorder and eating disorders (if present in past year); - Lack of response to an adequate trial of electroconvulsive therapy (ECT); - Prior treatment with TMS or a vagus nerve stimulator implant; - Pregnancy; - Personal or close family history of seizure disorder; - Presence of neurologic disorder or medication therapy known to alter seizure threshold; - Presence of ferromagnetic material in or in close proximity to head | Baseline N (ContinuationStudy) G1: 165 (44) G2: 160 (23) Current episode failures, meanG1: 1.6 G2: 1.6 Mean failed trials NR Previous treatment, not specified, % NR Polarity, % Unipolar 100 Age, mean yrs (Continuation Study) G1: 47.9 (49.2) G2: 48.7 (48.6) Sex, % females (Continuation Study) G1: 55.5% (54.5%) G2: 50.7% (47.8%) Race, % white (Continuation Study) G1: 94.2% (88.6%) G2: 89.7% (82.6%) HAM-D 17 Baseline score, mean (SD); Continuation Study G1: 22.6 (3.3); 6.5 (4.8) G2: 22.9 (3.5); 7.5(5.0) MADRS Baseline n (Continuation Study) G1: 155 (44) G2: 146 (23) Baseline score, mean (SD); Continuation Study G1: 32.8 (6.0); 9.0(8.2) G2: 33.9 (5.7); 10.9(8.1) IDS Baseline n (Continuation Study) G1: 155 (44) G2: 146 (23) Baseline score, mean (SD); Continuation Study G1: 42.0 (9.4); 14.4(9.8) G2: 43.4 (9.9); 13.4(9.4) CGI-S Baseline n (Continuation Study) G1: 155 (44) G2: 146 (23) Baseline score, mean (SD); Continuation Study G1: 4.7 (.6); 1.9(1.2) G2: 4.7 (.7); 2.3(1.0) | HAM-D 17 Analyzed n (Continuation study) G1: 155 (37) G2: 146 (19) Endpoint score, mean (SD) At week 4 G1: 17.4 (6.5) G2: 19.4 (6.5 At week 6 G1: 17.1 (7.7) G2: 19.6 (7.0) Change, mean (SD) At week 2 G1: -5.2 G2: -3.5 At week 4 (Continuation Study) G1: -14.6 (6.16) G2: -14.4 (6.11) At week 6 G1: -5.5 G2: -3.3 P = 0.005 At week 24 (Continuation Study) G1: -15.4(6.11) G2: -17.3 (5.07) Responders, n (%) At week 2 G1: 18 (11.6) G2: 13 (8.9) P > 0.10 At week 4 G1: 32 (20.6) G2: 17 (11.5) P < 0.05 At week 4 (continuation study) G1: 30(68.2) G2: 13 (56.5) At week 6 G1: 38 (24.5) G2: 20 (13.7) P < 0.05 At week 24 (continuation study) G1: 24(54.5) G2: 12(52.5) Remission rate n (%) HAM-D17 < 8 At week 2 G1: 5 (3.2) G2: 3 (2.1) P > 0.10 At week 4 G1: 110 (7.1) G2: 9 (6.2) P > 0.10 At week 4 (continuation study) G1: 19(43.2) G2: 10(43.5) At week 6 G1: 24 (15.5) G2: 13 (8.9) P = 0.065 At week 24 (Continuation Study) G1: 18 (40.9) G2: 10(43.5) MADRS Endpoint score, mean (SD) At 4 weeks G1: 27 (11.1) G2: 29.8 (10.1) At 6 weeks G1: 26.8 (12.8) G2: 30 (10.8) Change, mean (SD) At 4 weeks G1: 5.8 G2: 4.1 At 4 weeks (Continuation Study) G1: -21.2 (10.42) G2: -20.2(10.43) At 6 weeks G1: 6 G2: 3.9 At week 24 (Continuation Study) G1: -23(9.27) G2: -24.6(8.81) Response rate, % At week 2 G1: 8.4 G2: 6.2 P > 0.10 At week 4 G1: 18.1 G2: 11.0 P <0.05 At week 4 (Continuation Study) G129(65.9) G2: 12 (25.2) At week 6 G1: 23.9 G2: 12.3 P <0.01 At week 24 (continuation study) G1: 24 (54.5) G2: 11(47.8) Remission rate, % Remission defined as total score <10 At week 2 G1: 3.9 G2: 2.1 P > 0.10 At week 4 G1: 7.1 G2: 6.2 P > 0.10 At week 4 (Continuation Study) G1: 20(45.5) G2: 11(47.8) At week 6 G1: 14.2 G2: 5.5 P < 0.05 At week 24 (continuation study) G1: 18(40.1) G2:9(39.1) Other Relapse Rates: Relapse defined as recurrence of MDD per DSM-IV ≥ 2 weeks (HAM-D 17 ≥ 20; CGI-S ≥ 4) At week 4 (continuation study) G1: 2.3% G2: 7.8% At week 24 (continuation study) G1: 7.8% G2: 15.0% Symptomatic Worsening (% experiencing worsening) G1: 36.4% G2: 47.8% Kaplan-Meier Survival estimate of symptomatic deterioration G1: 37.4% G2: 60.8% In durability study combining rTMS responders Relapse, n (%) G1: 10 (10) G2: 3 (13.6) | Quality of Life Medical Outcomes Study Short Form-36 (MOS SF-36) Baseline n G1: 155 G2: 146 Baseline score, mean (SD) Mental Component Score G1: 20.4 (8.05) G2: 20.4 (7.76) Physical Component Score G1: 50.5 (11.01) G2: 48.8 (10.35) Endpoint Score NR Change, mean (SD) Mental Component Score At week 4 G1: 4.5 (10.16) G2: 2.0 (9.42) P = 0.019 At week 6 G1: 5.7 (12.65) G2: 2.9 (10.6) P = 0.032 Physical Component At week 4 G1: 0.3 (7.52) G2: 0.2 (7.28) P = 0.892 At week 6 G1: 0.1 (7.49) G2: -0.2 (7.23) P = 0.682 Quality of Life, Enjoyment and Satisfaction Questionnaire –Short Form (Q-LES-Q) Baseline n G1: 155 G2: 146 Baseline score, mean (SD) G1: 37.8 (8.23) G2: 36.5 (7.87) Endpoint score, mean (SD) At week 4 G1: 41.4 (10.32) G2: 39.0 (9.78) At week 6 G1: 42.2 (12.28) G2: 39.0 (10.15) Change, mean (SD) At week 4 G1: 3.50 (9.19) G2: 3.80 (11.58) At week 6 G1: 2.0 (9.24) G2: 1.3 (9.85) Other Active rTMS vs. Sham P = 0.035 at week 6 Adverse Events Serious adverse events G1: 6 G2: 5 Suicidality, % G1: 0.6 G 2: 1.9 Exacerbation of depression, % Active TMS: 0.6 Sham TMS: 1.9% Eye pain: active, % TMS: 6.1 Sham TMS: 1.9%; GI disorders toothache, % Active TMS: 7.3 Sham TMS: 0.6 Application site discomfort, % TMS: 10.9 Sham: 1.3% Application site pain, %: TMS: 35.8 Sham: 3.8 Facial pain, % Active TMS: 6.7 Sham TMS: 3.2 Muscle twitching, % TMS: 20.6 Sham: 3.2 Pain of skin, % TMS: 8.5 TMS: 0.6% Adverse Events (Continuation Study)Constipation: G1: 0 G2: 0 Dry Mouth: G1: 0 G2: 0 Application Site Pain: G1: 6.8%G2: 26.1% Arthralgia: G1: = 2.3%, G2 = 0 Muscle Twitching: G1: = 4.5%, G2 = 13.0% Headache: G1: = 6.8%, G2 = 8.7% Insomnia: G1: 0 G2: 0 MMSE NR Attrition Overall, % 15 At end of treatment, % G1: wk2 6%/ wk 4 5% G2: wk 2 9%/ wk 4 6% At end of follow-up, % NR Withdrawals due to efficacy, % G1: 0.6% G2: 1% Withdrawals due to adverse events, % G1: 5% G2: 4% Other 325 subjects were randomized 24 were “nonevaluable” 301 continued to receive at least 1 treatment, these 301 were included in final analysis 277 completed study through week 4. Adherence/ compliance NR
Author, Year Stern et al., 2007^32^ Country, setting NR, outpatient setting Funding The Milton Fund, NARSAD,Stanley Vada NAMI Foundation, NIMH, Spanish Ministerio de Educacion y Cienca Research Objective To testhypothesis that rTMS exerts antidepressant effects either by enhancing left dorsolateral prefrontal cortex (DLPFC) excitability (using high-frequency rTMS) or by decreasing right DLPFC excitability (using low-frequency rTMS) have equivalent an Quality Rating Fair | Study design RCT Type of analysis Cannot tell, all reported patients included in the analysis N 45 Duration; - 10 days (2 wk) stimulation and 2 wk f/u for all 4 gps; - An additional 2 wk of unblinded f/u with gp 1 & 3 to assess for relapse.; Primary Outcome: HAM-D at 2 weeksnd and 2 weeks after treatment Interventions G1: 10 Hz rTMS to left DLPFC G2: 1 Hz rTMS to left DLPFC G3: 1 Hz toright DLPFC G4: Sham rTMS Medications allowed No psychotropic medications were allowed Parameters rTMS High Frequency:; - Frequency (Hz):10; - Motor threshold (%): 110; - Number of trains: 20; - Length of train (seconds): 8; - Inter-train interval: 52; - Pulses per session: 1600; - Total number of sessions: 10 days; Low Frequency LDLPFC:; - Frequency (Hz):1; - Motor threshold (%): 110; - Number of trains: 1; - Length of train (seconds): 1600; - Inter-train interval: 1; - Pulses per session: 1600; - Total number of sessions: 10 days; Low Frequency RDLPFC:; - Frequency (Hz): 1; - Motor threshold (%): 110; - Number of trains: 1; - Length of train (seconds): 1600; - Inter-train interval: 1; - Pulses per session: 1600; - Total number of sessions: 10 days; Sham rTMS:; - Orientation of coil perpendicular to scalp subdivided into 3 groups, replicating parameters for each group above; Strategy Switch | TRD definition; - All referred for ECT having failed an adequate course of antidepressant med; - Required to be in current episode; Tier 2 Inclusion criteria; - Patients w unipolar recurrent major depressive disorder (SCID & DSM-IV) HAM-D21 score ≥ 20; Exclusion criteria; - H/O any psychotic disorder (incl. schizophrenia or schizoaffective disorder); - Bipolar disorder; - Obsessive compulsive disorder; - Personality disorder; - SA(except nicotine) within past yr; - Current acute/chronic medical condition requiring txt with psychoactive medication; - H/O epilepsy or unprovoked seizures or other neurological disorder; - Abnormal neurological examination; - Family H/O medication-resistant epilepsy; - Prior brain surgery; - Metal in head; - Implanted medical device; - Pregnancy | Treatment Failure Mean failed trials NR Polarity, % Unipolar 100 % MDD Age, mean yrs G1: 53.2 G2: 52.3 G3: 52.8 G4: 53.3 Sex, % females G1: 60 G2: 60 G3: 70 G4: 60 Right handed, % 100 HAM-D 21 Baseline n G1: 10 G2: 10 G3: 10 G4: 15 Baseline score, mean (SD) G1: 27.8 (3.2) G2: 27.6 (3.9) G3: 27.9 (3.8) G4: 27.4 (2.9) | HAM-D 21 Endpoint score, mean (SD) At week 1 G1: 22.2 (5.6) G2: 27.6 (5.9) G3: 20.9 (4.1) G4: 25.6 (4.5) At week 2 G1: 15.1 (6) G2: 27.6 (5.9) G3: 15.8 (4.8) G4: 26.7 (3.6) Week 1 Follow-up G1: 12.8 (5.7) G2: 26.4 (2.3) G3: 15.3 (6.4) G4: 26.5 (2.3) Week 2 Follow-up G1: 13.4 (5.6) G2: 26.6 (3.0) G3: 14.9 (5.9) G4: 26.8 (2.3) Change, mean (SD) At week 2 G1: -12.7 G2: 0.0 G3: -12.1 G4: -0.7 % change, P = 0.001 2 week follow-up G1: 0 G2: 1.0 G3: 13.0 G4: 0.6 % change, P = 0.00001 Responders, n At week 1 G1: 0 G2: 0 G3: 0 G4: 0 At week 2 G1: 2 (50%) G2: 0 (0%) G3: 5 (50%) G4: 0 (0%) G1/G3 vs. G2/G4 (P < 0.0005) 1 week follow-up G1: 6 (60%) G2: 0 (0%) G3: 6 (60%) G4: 0 (0%) G1/G3 vs. G2/G4 (P < 0.0005) 2 week follow-up G1: 4 (40%) G2: 0 (0%) G3: 6 (6%) G4: 0 G1/G3 vs. G2/G4 (P < 0.0005) Remitters, n HAM-D ≤ 10 At week 1 G1: 0 (0%) G2: 0 (0%) G3: 0 (0%) G4: 0 (0%) At week 2 G1: 3 (30%) G2: 0 (0%) G3: 1 (10%) G4: 0 (0%) 1 week follow-up G1: 4 (40%) G2: 0 (0%) G3: 3 (30%) G4: 0 (0%) 2 week follow-up G1: 4 (40%) G2: 0 (0%) G3: 3 (30%) G4: 0 (0%) Responders followed for additional two weeks (endpoint 2wk follow-up) G1: vs. G3 P = NS (all times); G2 vs. G4 and G1: vs. G3 P = NS (all times) | Quality of Life NR Adverse Events 9/45 pts reported severe headaches (pts by group NR); no seizures Attrition Overall, %: 17.8 At end of treatment, % G1: 0 G2: 20 G3: 0 G4: 10 At end of follow-up, % G1: 0 G2: 50 G3: 0 G4: 20 Withdrawals due to efficacy: NR Withdrawals due to adverse events, % G1: 0 G2: 50 G3: 0 G4: 20 Though 8 pts withdrew due to AE, only 3 of those were listed as w/d during active period. Reported in text as dropped out following week 2. Adherence/ compliance NR
Author, Year Bortolomasi et al., 2006^34^ Country, setting Italy, single center, inpatient vs. outpatient NR Funding Not reported Research Objective To investigate outcome of depressed patients treated for 1 month with high frequency rTMS onleft frontal lobe at long time periods Quality Rating Fair | Study design RCT Type of analysis Cannot tell, all reported patients included in analysis N 19 Duration Active: 5^*^ days Follow-up: 1, 4 and 12 weeks, co –primary endpoints HAM-D and BDI *duration of txt is unclear in article Interventions G1: rTMS G2: Sham Medications allowed Patients continued their (failed) ADs and no medications changes were allowed (5.3% were not taking medications at study entry) Strategy Augmentation Allowed to continue on failed SSRIs (63.2%) and TCAs (26.3%), No meds (5.3%) Parameters rTMS; - Frequency (Hz):20; - Motor threshold (%): 90; - Number of trains: 20; - Length of train (seconds): 2; - Inter-train interval: 60; - Pulses per session: 800; - Total number of sessions: 5/wk; - Circular coil; Sham; - Stimulation coil was placed perpendicular tothe scalp surface without direct contact. Coil position was fixed for all TMS sessions, and stimulation at this site evoked minimal motor activity | TRD definition; - Drug resistance (not defined); - Not required or not specified to be in current episode; Tier 3 Inclusion criteria; - DSM-IV clinical criteria for major depression, right-handed, normal neurological examinations; Exclusion criteria; - Hx of brain trauma or seizure disorder; - Pacemakers, mobile metal implants or implanted medication pumps | Treatment Failure Mean failed trials NR Polarity, % Unipolar G1: 83.3 G2: 85.7 Bipolar G1: 16.7 G2: 14.3 Age, mean yrs G1: range 45-56 G2: range 44-53 Overall: 55.6 Sex, % females G1: 58 G2: 57 Race, % white NR Right handed, % Overall: 100 Groups similar at baseline Yes Tier HAM-D 24 Baseline n G1: 12 G2: 7 Baseline score, mean (SD) G1: 25.17 G2: NR | HAM-D 24 Endpoint score, mean (SD) At week 1 G1: 11.33 G2: 18.29 At week 4 G1: 11.42 G2: 19.14 At week 12 NR Change, mean (SD) At week 1 G1: -13.84 G2: NR P = NR, significant Group × time at wk 2 and 4, P < 0.05 At week 4 G1: -13.75 G2: NR At week 12 NR IG1: rTMS G2: Sham Baseline n G1: 12 G2: 7 Baseline score, mean (SD) G1: 25.42 G2: NR Endpoint score, mean (SD) At week 1 G1: 12.25 G2: 22.43 At week 4 G1: 11.67 G2: 24.57 Change, mean (SD) At week 1 G1: 13.17G2: NR At week 4 G1: 13.75 G2: NR | Quality of Life NR Adverse Events No adverse effects were reported in either group, except for mild cephalgia by 3 patients treated with anti-inflammatory drugs Headache, %; - 3 patients reported mild headaches after treatment; - All rTMS patients referred to marked drowsiness for several hours immediately following. Six patients referred to subjective improvement of sleep after first stimulation session. Patients treated with sham condition did not report any symptoms related to drowsiness or sleep.; - 3 patients reported mild headaches after treatment; Attrition NR Adherence/ compliance NR
Author, Year McLoughlin et al., 2007^7^ Eranti et al., 2007^8^ Knapp et al., 2008^9^ Country, setting UK, South London and Maudsley NHS Trust and Pembury Hospital inInvicta Mental Health Trust in Kent, 65.2% were inpatients Funding National Health Service Research and Development, National Coordinating Centre for Health Technology Assessment (NCCHTA) (98/11/04); byGuy's and St. Thomas's Charitable Foundation (R001126); and by a 2003 Ritter Independent Investigator Award from National Alliance for Research on Schizophrenia and Depression. Research Objective To assess clinical effectiveness of rTMS vs. ECT for treating major depressive episodes in patients referred for ECT Quality Rating Good | Study design RCT- pragmatic and single blinded (raters) Type of analysis m-ITT N 46 Duration Primary endpoint at 3 weeks for rTMS and at clinicians discretion for ECT, additional follow-up at 6 months Interventions G1: ECT G2: rTMS Medication Allowed Patients continued their usual medical care and stable psychotropic medications were allowed (i.e. SSRIS, TCAs, Venlafaxine, Mirtazapine, Lithium, Anticonvulsant mood stabilizers, Benzodiazepines, Antipsychotics, Zopiclone, L-Tryptophan) Strategy Augmentation Parameters rTMS; - Frequency (Hz): 10; - Motor threshold (%):110; - Number of trains: 20; - Length of train (seconds): 5; - Inter-train interval: 55; - Pulses per session: 1000; - Total number of sessions: daily for 15 days; ECT:; - % receiving bilateral: 82; - Intensity: 1.5 × ST for bilateral frontotemporal ECT and 2.5 × ST for right unilateral ECT; - Number of sessions (range, mean, SD): range = 2-10, mean = 6.3, SD = 2.5 | TRD definition; - All patients referred for ECT:; - No failure required; Tier 3 Inclusion criteria; - Right handed patients; - more than 18 years old; - refered for ECT due to major depressive episode; Exclusion criteria; - Inability to have rTMS because of metallic implants or foreign bodies; - History of seizures; - Substance misuse in previous 6 months; - Being medically unfit for general anesthesia or ECT:; - ECT or rTMS in previous 6 months,; - Dementia or other axis I diagnosis; - Inability or refusal to provide informed consent. | Treatment Failure Mean failed trials G1: 2.5 (1.4) G2: 2.4 (1.0) Polarity, % MDD G1: 91.67 G2: 90.91 Bipolar G1: 8.33% G2: 9.09 % Age, mean yrs G1: 63.6 G2: 68.3 Sex, % females G1: 67.7 G2: 72.7 Right handed, % Overall: 100% HAM-D 17 Baseline n G1: 22 G2: 24 Baseline score, mean (SD) G1: 24.8 (5.0) G2: 23.9 (7.0) BDI: Baseline score, mean (SD) G1: 36 (8.7) G2: 37.8 (10.5) | HAM-D 17 Analyzed n G1: 22 G2: 23 Endpoint score, mean (SD) End of treatment G1: 10.7 G2: 18.5 P = 0.002, effect size of 1.44 Follow-up at 6 months G1: NR G2: NR P = 0.93 Change, mean (SD) End of treatment G1: -14.1 G2: -5.4 P = 0.017 Responders, n End of treatment G1: 13 (59.1%) G2: 4 (17.4%) P = 0.005 Remitters, n HAM-D ≤ 8 End ot treatment G1: 13 (59.1%) G2: 4 (17.4%) P = 0.005 Follow-up at 6 months^*^ G1: 6 (27.4%) G2: 2 (8.7%) *only 12 ECT remitters followed after End of txt BDI Endpoint score, mean (SD) NR P = 0.01 effect size=0.9 Change, mean (SD) NR Group × time, P = 0.25 Responders, n NR Remitters, n NR | Quality of Life SF-36 mental health component score Baseline n G1: 24 G2: 22 Baseline score, mean (SD) G1: 48.9 (12.6) G2: 42.7 (7.5) Other: QALYs Six month QALY gain, mean (SD) G1: 0.0300 (0.053) G2: 0.0297 (0.056) (QALYs were derived using SF-36 data). At six month follow-up, service use data were collected on 28 pts (10-ECT and 18-rTMS). Patients responded much better to ECT than to rTMS by the end of the allocated treatment course. The differential QALY gain of treatment with rTMS over ECT was 0.0003 (p = 0.987). This suggests that treatment by rTMS does not provide any additional gains in quality of life over ECT over a 6-month period. The lack of a statistically significant difference in QALY gain between the two groups may reflect lack of difference in HRSD scores between groups at 6 months. Adverse Events NR Neuropsychological or executive functioning Predefined CAMCOG Attention and orientation subscale (max = 17): ECT baseline 12.8 (3.2), end of treatment 13.9 (3.6), 6mos 13.9 (3.5) rTMS baseline 14.7 (3.0) end of treatment 13.5 (3.3) FU6mos 13.4 (3.8), P = 0.004 No significant differences for rest of CAMCOG subscales (verbal fluency, anterograde memory, and retrograde memory) MMSE Baseline score, mean (SD) G1: 24.3 (3.6) G2: 25.7 (3.9) Score at 6 months, mean (SD) G1: 25.4 (5.3) G2: 24.7 (4.8) Endpoint score, mean (SD) G1: 25.6 (3.9) G2: 24.4 (5.3) Change, mean (SD): G1: 1.3 G2: -1.3 P < 0.08 No significant differences on the Columbia ECT Subjective Side Effects Schedule for self-reported cognitive side effects. Attrition Overall to end of treatment 6/46, at 6 months 9/46 At end of treatment, % G1: 6/24 G2: 0 At end of follow-up, % NR Withdrawals due to efficacy, % G1: 5/24 G2: 0 Withdrawals due to adverse events, % 0 Adherence/ compliance NR
Author, Year Paykel, 1999^38^ Scott, 2000^59^ Scott, 2003^60^ Paykel, 2005^61^ Note: #2223, #2219, #274, and #3815 are companion studies, data was abstracted in toform for #2219. Country, setting UK, outpatient Retrospective analysis: Inpatient or Outpatient Funding Medical Research Council, London, England and a grant fromOxford and Anglia Region Research Objective To compare cognitive therapy combined with clinical management to clinical management alone for patients with residual depressive symptoms who continued to receive maintainance treatment with antidepressants. Retrospective analysis: To restudy subjects approximately 6 years after randomization, or 4 1/2 years after completion of the trial and its follow-up phase Quality Rating Fair | Study design RCT Type of analysis ITT N 158 Retrospective analysis: 135 Duration Treatment period = 20 weeks; 48 wks - follow-up: Subjects were assessed every 4 to 20 wks and every 8 wks thereafter at baseline, 8 wks, 20 wks, and 68 wks. Retrospective analysis: wks 69 and onward (up to 6 years) Interventions G1: Clinical management Only G2: CT plus Clinical Management Retrospective Analysis G3: Clinical management only G4: CT plus Clinical Management Medications allowed Continued on current medications with dose adjustments allowed Strategy Augmention Parameters Psychotherapy:; - Type of therapy: Cognitive Therapy; - Method: Individual; - Number of sessions/week: 1.25/wk; - Total number of sessions: 16 | TRD definition; - residual symptoms reaching at least 8 on the 17-item Hamilton Depression Rating Scale (HDRS)18 and 9 on the Beck Depression Inventory (BDI) and taking a tricyclic antidepressant, serotonin reuptake inhibitor, atypical antidepressant, or monoamine oxidase inhibitor for at least the previous 8 weeks, with 4 or more weeks at a daily dose at least equivalent to 125 mg of amitriptyline,; - Residual symptoms had lasted 2 to 18 months.; - Failure required to be in the current episode; - Retrospective Analysis Relapse defined as return to Major depression for 4 wks or, during the follow-up trial phase only, persistent residual symptoms for at least 8 weeks reaching 13 on the HAM-D in two successive rating 8 wks apart and producing a sufficient level of distress or dysfunction to mandate withdrawal from treatment constraints.; Tier 2 Inclusion criteria; - Unipolar depression,; - aged 21 to 65 years,; - satisfying DSM-III-R17 criteria for major depression withinlast 18 months but not inlast 2 months, and; - Had to be taking a tricyclic antidepressant, serotonin reuptake inhibitor, atypical antidepressant, or monoamine oxidase inhibitor for at leastprevious 8 weeks, with 4 or more weeks at a daily dose at least equivalent to 125 mg of amitriptyline, and higher levels unless there were definite current adverse effects or patient refusal to increase dose.; Exclusion criteria; - A history of bipolar disorder, cyclothymia, schizoaffective disorder, definite; - Intervention or alcohol dependence, persistent antisocial behavior or repeated self-harm,; - DSM-III-R dysthymia with onset before age 20 years,; - borderline personality, learning disability (estimated IQ,70),; - organic brain damage,; - any other primary Axis I disorder attime ofindex illness.; - Also excluded were patients currently receiving formal psychotherapy or those who had previously received CT for more than 5 sessions. | Treatment Failure Mean failed trials G1: NR G2: NR Retrospective analysis: G3: NR G4: NR Polarity, % Unipolar 100% Retrospective analysis: G3: NR G4: NRAge, mean yrs G1: 43.2 (11.2) G2: 43.5 (9.8) Retrospective analysis: G3: 48.6 G4: 49.8 Sex, % females G1: 53% G2: 46% Retrospective analysis: G3: 52% G4: 50% HAM-D 17 Baseline n G1: 78 G2: 80 Baseline score, mean (SD) G1: 12.2 (2.9) G2: 12.1 (2.7) BDI Baseline score, mean (SD) G1: 22.3 (8.0) G2: 21.9 (7.7) | HAM-D 17 G1: Clinical Management only G2: CT plus Clinical Management Endpoint score, mean (SD) At week 20 G1: 9.40 (5.2) G2 (5.2) Follow up at 44 weeks G1: 8.7 (5.3) G2: 7.6 (4.7) Follow up at 68 weeks G1: 7.2 (4.7) G2: 7.2 (5.3) Retrospective analysis: Mean scores at end of study G3: 7.3 (5.5) G4: 8.0 (6.4) Change, mean (SD) At week 20 G1: -2.8 G2: -3.4 P = NS Follow up at 44 weeks G1: - 3.0 G2: -4.5 Follow up at 68 weeks G1: -5.0 G2: -4.9 Responders, n NR Remitters, n (%) HAM-D<8 At week 20 G1: 10 (13) G2: 19 (24) Hazard Ratio for remission from intention to treat analysis: 2.42 (95% CI, (1.08, 5.45)) Retrospective analysis: Remission by 68 weeks G3: 30 G4: 42 BDI Endpoint score, mean (SD) At 20 weeks G1: 16.1 (10.0), G2: 13.8 (9.6), Follow up at 44 weeks G1: 17.3 (11.6) G2: 12.3 (9.3) Follow up at 68 weeks G1: 14.3 (10.9) G2: 13.5 (11.7) Change, mean (SD) At week 20 G1: -6.24 G2: -8.44 Responders, n NR Remitters, n BDI <9 At week 20 G1: 10 (13%) G2: 19 (24.4%) Relapse n(%): At week 20: G1: 18 (23) G2: 10 (13) At week 44 G1: 40 (51) G2: 24 (30) At week 68 G1: 47 (60) G2: 29 (36) Hazard ratio for relapse = 0.54 (0.32-0.93) in favor of CT Actuarial Cumulative relapse rates at all time points for group 1: Awk20 = 18%, FUwk44 = 40%, FUwk68 = 47%; Actuarial Cumulative relapse rates at all time points for group 2: Awk20 = 10%, FUwk44 = 24%, FUwk68 = 29%;adjusted hazard ratio for relapse = 0.51, 95% CI (0.32, 0.93). Over 17 months,relapse rate was reduced from 47% among those who continued to be treated with antidepressants without CT to 29% among those who also received CT. #2219: Relapse was defined as: (1) meetingDSM-III criteria for major depressive disorder for a minimum of 1 month, and meeting severity criteria for major depression and score 17 or more onHAM-D 17 at 2 consecutive face-to-face assessments at least 1 week apart; (2) persistent residual symptoms during follow up phase between 2 successive ratings 2 months apart, reaching a score onHAM-D 17 of at least 13 on both occassions and a level of distress or dysfunction for which the withholding of additional active treatment was no longer justified Retrospective Analysis Acutarial Kaplan-Meier recurrence rates (%): Wk 20 (from randomization): G1: 24 G2: 5 Difference (95% CI), p-value: 19 (8 to 30), p = 0.002 Wk 68 (from randomization): G1: 34 G2: 23 Difference (95% CI), p-value: 11 (-3 to 25), p = 0.07 Wk 120(from randomization): G1: 43 G2: 83 Difference (95% CI), p-value: 5 (-11 to 21), p = 0.25 Wk 172 (from randomization): G1: 49 G2: 41 Difference (95% CI), p-value: 8 (-8 to 24), p = 0.16 Wk 224 (from randomization): G1: 55 G2: 56 Difference (95% CI), p-value: -1 (-17 to 15), p = 0.52 Wk 275 (from randomization): G1: 65 G2: 60 Difference (95% CI), p-value: 5 (-11 to 21), p = 0.33 | Quality of Life NR Adverse Events NR Attrition Overall, % 20% did not adhere to protocol through to study end or relapse point Retrospective analysis: 14.5% Reasons for Overall Attrition: Deceased, n= 7; Refused, n = 11; Non-response to request, n = 3, Not traceable, n = 2 At end of treatment, % G1: 4 G2: 14 At end of followup, % G1: 12 G2: 10 Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR Adherence/ compliance Adherence, n(%) G1: 61 (76%) G2: 66 subjects (85) [Control]

* This study came from an unpublished source (conference proceeding).

Evidence Table 11 KQ 3 – Tier 3: Maintaining remission or treating patients with unresponsive or recurrent disease

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Grunhaus et al., 2000^62^ Country, setting Israel Sheba Medical Center, inpatients and outpatients Funding Established Investigator Award of NARSTAD Research Objective To compare rTMS to ECT and psychotic vs. non-psychotic Quality Rating Poor | Study design RCT Type of analysis ITT N 40 Duration Varied – ECT patients treated for average of 5 weeks, and rTMS pts treated for 4 weeks. Primary outcome measured at end of treatment Interventions Overall G1: ECT G2: rTMS Pts with psychosis G3: ECT: G4: rTMS Pts without psychosis G5: ECT G6: rTMS Medications allowed; - ECT allowed benzodiazepines, neuroleptics antidepressants and anticonvulsants in stable doses; - rTMS All psychiatric medications were discontinued only clonazepam (1–2 mg/day, given in twice-daily doses) was started in all patients to decrease anxiety, provide relief of severe insomnia, and have an additional protective element regarding seizures; Strategy Mixed-between group differences Parameters ECT:; - % receiving bilateral: 40 switched after non-response; - Intensity 2.5-fold seizure threshold; - Number of sessions -mean 9.6 sessions (range 7-14); rTMS Low; - Frequency (Hz):; - Motor threshold (%):; - Number of trains:; - Length of train (seconds):; - Inter-train interval:; - Pulses per session:; - Total number of sessions:; rTMS High; - Frequency (Hz):; - Motor threshold (%):; - Number of trains:; - Length of train (seconds):; - Inter-train interval:; - Pulses per session:; - Total number of sessions: | TRD definition; - Pts referred for ECT; - Only some patients treatment resistant (not defined). Treatment failure not required or not specified to be in current episode; Tier 3 Inclusion criteria; - age over 18; - DSM-IV diagnosis of MDD; - HAM-D17 ≥18; - no personal or first-degree relative history of seizure; - no medical, neurological, or neurosurgical disorder that would precludeadministration of ECT or rTMS.; Exclusion criteria; - Additional Axis-1 diagnoses | Subgroups Patients with and with out Psychosis Treatment Failure Failed ≤1 trial, % G1: 50 G2: 25 Failed ≥2 trials, % G1: 50 G2: 75 Polarity, % 100% MDD Age, mean yrs G1: 63.6 (15.0) G2: 58.4 (15.7) Sex, % females G1: 70 G2: 60 HAM-D 17 Baseline n Overall G1: 20 G2: 20 Patients with Psychosis G3: 10 G4: 9 Patients without Psychosis G5: 10 G6: 11 Baseline score, mean (SD) G1: 28.4 (9.3) G2: 25.8 (6.1) G3: 31.5 (11.5) G4: 28.7 (5.6) G5: 25.2 (5.3) G6: 23.5 (5.6) | HAM-D 17 Endpoint score, mean (SD) At week 2 G1: 17.6 (7.4) G2: 19.3 (8.6) G3: 15.5 (7.6) G4: 23.4 (5.5) G5: 19.7 (7.0) G6: 15.8 (9.3) End of treatment G1: 11.2 (8.4) G2: 15.4 (7.5) G3: 8.4 (5.3) G4: 20.8 (5.0) G5: 13.9 (10.3) G6: 11.0 (6.2) Change, mean (SD) At week 2 G1: 10.8 G2: 6.5 G3: 16.0 G4: 5.3 G5: 5.5 G6: 7.7 End of treatment G1: 17.2 G2: 10.4 Group × time, P = 0.09 G3: 23.1 G4: 7.9 Group × time, P = 0.005 G5: 11.3 G6: 12.5 Group × time, P = NS Responders if the final HRSD had decreased to 50% or more from baseline and the final GAS < 60. Responders, n End of txt G1: 16 (80%) G2: 9 (45%) P < 0.05 G3: 10 (100%) G4: 2 (22%) P ≤ 0.01 G5: 6 (60%) G6: 7 (63%) P = NS | Quality of Life Scale Pittsburg Sleep Quality Index Intervention G1: ECT G2: rTMs G3: G4: ECT Psychotic vs none G5: rTMS Psychotic vs none Baseline n G1: 20 G2: 20 G3: G4: 10 vs. 10 G5: 9 vs. 11 Baseline score, mean (SD) G1: 12.5 (4.4) G2: 11.7 (5.7) G3: G4: 12.1 (5.5) vs 12.9 (3.1) G5: 14.1 (4.9) vs 9.7 (5.8) Endpoint score, mean (SD) G1: Awk2 8.8 (4.5)/endpoint 6.8 (3.5) G2: Awk2 10.1 (3.7)/endpoint 10.5 (3.9) G3: G4: Awk2 8.0 (4.5)/endpoint 5.8 (2.1) vs Awk2 8.0 (4.5)/endpoint 5.8 (2.1) G5: Awk2 12.2 (2.8)/endpoint 12.3 (3.6) vs. Awk2 8.4 (3.5)/endpoint 9.1 (3.8) Change, mean (SD) G1: Awk2 3.7/endpoint 5.7 G2: Awk2 1.6/endpoint 1.2 G3: G4: Awk2 4.1/endpoint 6.3 vs Awk2 4.9/endpoint 7.1 G5: Awk2 11.9/endpoint 1.8 vs. Awk2 1.3/endpoint 0.6 Other Overall Group F 1.8 (df 1,36) P = NS Time F 12.5 (df 2,72) P = 0.000 Interaction F 4.6 (df 2,2) P = 0.010 Non-psychotic Group F 0.5 (df 1,18) P = NS Time F 4.4 (df 2,36) P = 0.020 Interaction F 2.3 (df 2,2) P = NS Psychotic Group F 9.8 (df 1,16) P = 0.006 Quality of Life Overall Group F 1.8 (df 1,36) P = NS Time F 12.5 (df 2,72) P = 0.000 Interaction F 4.6 (df 2,2) P = 0.010 Non-psychotic Group F 0.5 (df 1,18) P = NS Time F 4.4 (df 2,36) P =0.020 Interaction F 2.3 (df 2,2) P = NS Psychotic Group F 9.8 (df 1,16) P = 0.006 Scale Global Assessment of Function Scale Intervention G1: ECT G2: rTMS G3: G4: ECT Psychotic vs none G5: rTMS Psychotic vs none Baseline n G1: 20 G2: 20 G3: G4: 10 vs. 10 G5: 9 vs. 11 Baseline score, mean (SD) G1: 31.0 (8.5) G2: 34.1 (11.7) G3: Intervention4: 29.0 (7.0) vs. 33.0 (9.8) G5: 28.9 (9.9) vs. 38.3 (11.8) Endpoint score, mean (SD) G1: Awk2 46.8 (17.2)/endpoint 61.5 (21.5) G2: Awk2 44.5 (14.7)/endpoint 51.0 (18.2) G3: G4: Awk2 50.6 (18.3)/endpoint 65.5 (18.8) vs. Awk2 43.0 (16.0)/endpoint 57.5 (24.2) G5: Awk2 36.1 (8.2)/endpoint 39.4 (14.5.) vs. Awk2 51.4 (15.5)/endpoint 60.5 Change, mean (SD) G1: Awk2 15.8/endpoint 30.5 G2: Awk2 10.4/endpoint 16.9 G3: G4: Awk2 21.6/endpoint 36.5 vs. Awk2 10.0/endpoint 24.5 G5: Awk2 7.2/endpoint 10.5 vs. Awk2 13.1/endpoint 22.2 Other Overall Group F 0.7 (df 1,38) P = NS Time F 40.8 (df 2,76) P = 0.000 Interaction F 3.4 (df 2,2) P = 0.040 Non-psychotic Group F 1.0 (df 1,19) P = NS Time F 19.8 (df 2,38) P = 0.000 Interaction F 0.3 (df 2,2) P = NS Psychotic Group F 8.2 (df 1,17) P = 0.01 Adverse Events NR 5 rTMS patients had mild headaches Neuropsychological or executive functioning Measures, Results MMS. (ECT baseline 25.9 (4.1), ECT end of treatment 24.5 (7.6); rTMS baseline 24.8 (4.1), rTMS end of treatment 26.3 (3.9), repeated measures ANOVA [group effect F(1,29) = 0.1, P = NS; time effect F(2,58) = 1.3, P = NS; interaction F(2,2) = 2.3, P = NS) analysis was also performed forpsychotic– nonpsychotic groups with similar results. Predefined No MMSE Baseline n G1: 20 G2: 20 Baseline score, mean (SD) G1: 25.9 (4.1) G2: 24.8 (4.1) Endpoint score, mean (SD) G1: 24.5 (7.6) G2: 26.3 (3.9) Change, mean (SD) G1: -1.4 G2: +1.5 Other ANOVA [group effect F(1,29) = 0.1, P = NS; time effect F(2,58) = 1.3, P = NS; interaction F(2,2) = 2.3, P = NS) analysis was also performed forpsychotic– nonpsychotic groups with similar results. Adequate information Attrition Overall, % 0% At end of treatment, % 0 At end of followup, % 0 Withdrawals due to efficacy, % 0 Withdrawals due to adverse events, % 0 Adherence/ compliance Compliance All patients completed study
Author, Year Dannon, 2002^45^ Country, setting Israel; medical center outpatient program Funding National Association for Research in Schizophrenia and Affective Disorders NARSAD) and Stanley Research Foundation Research Objective To compare longitudinal outcomes of patients who responded to either rTMS or ECT Quality Rating Fair | Study design Observational Type of analysis Study references Grunhaus 2000 (Refid #368) which is open study of 40 patients -suspect this is continuation of this with additional patients. Of 43 responders initially identified, 2 are excluded N 43 Duration 3 month and 6 month follow-up; Primary outcome was presence or absence of relapse at 3 or 6 months. Relapse defined as return of depressive symptomatology meeting DSM-IV criteria for MDD with a HAM-D17 score of >= 16 points Interventions A - Electroconvulsive Therapy (ECT)B - Repetetive Transcranial Magnetic Stimulation (rTMS) G1: ECT G2: rTMS Antidepressants prescribed at end of ECT and rTMS for all patients Parameters rTMS: Location = Left Dorsolateral Prefrontal Cortex Frequency = 10Hz Intensity = 90% MT Per Session = 6 sec trains with 30 sec interval in between at 20 times. Number of sessions = daily for 20 days ECT Methods: Location: Initially unilateral; switched to bilateral txt after 6th txt if HRSD had not decreased by >= 30% Threshold = 2.5 times threshold energy to maintain a seizure length of >= 25 sec. Number of sessions = NR Strategy There is no description of whether participats were taking medications prior to treatment with ECT or rTMS. Co-medications were not allowed during period when ECT or rTMS was given with exception of lorazepam. Antidepressants | TRD definition; - Not required or not specified to be in current episode; Setting(s) Outpatient Inclusion criteria; - Responded to treatment with either ECT or rTMS; - over age 18 years; - DSM-IV diagnosis of MDD with or without psychotic features; - no personal or first-degree family history of seizure; - no major medical, neurologic, or neurosugical disorder.; - Response for inclusion defined as HAM-D17 <= 10 or demonstrating 60% drop in HAM-D and final global assessment scale (GAS) >=60; Exclusion criteria NR in this article - but Grunhaus 2000 (Refid #368) reports that patients with additional axis-I diagnoses were excluded from the study | Subgroups No sub-group analysis of psychosis although permitted in study Treatment Failure Patients referred for ECT because of nonresponse or psychotic MDD Failed 1 or more, % G1: NR G2: NR Failed 2 or more, % G1: NR G2: NR Current episode failures, mean G1: NR G2: NR Mean failed trials G1: NR G2: NR Previous treatment, not specified, % G1: NR G2: NR Polarity, % Unipolar G1: NR G2: NR Bipolar I G1: NR G2: NR Bipolar II G1: NR G2: NR Age, mean yrs G1: 57.43 G2: 56.85 Sex, % females G1: 70% G2: 66.7% Note: there might be a typo in table in reporting gender ratio, percentage reported here is based on numbers in"rTMS" column in paper because they add up to correct n for “ECT column.” Race, % white G1: NR G2: NR Right handed, % G1: NR G2: NR Groups similar at baseline No- what are differences All P values were reported as nonsignificant for baseline characteristics, however following characteristics showed some variation between groups: Duration of episode (months) (mean +/- SD), ECT grouP = 6.71 +/-7.56, rTMS gr Tier Tier 3 only mention of whether participants failed any previous treatments is in Grunhaus (#368). | HAM-D 17 Baseline n 1: 20 G2: 21 Baseline score, mean (SD) G1: 7.90 (4.54) G2: 7.75 (3.74) Endpoint score, mean (SD) At 3 months G1: 7.71 (5.03) G2: 6.40 (4.91) At 6 months G1: 8.40 (5.60) G2: 7.90 (7.14) Change, mean (SD) At 3 months G1: -0.01 G2: 1.35 At 6 months G1: -0.5 G2: -0.15 Responders, n NR Remitters, n NR Relapse (HAM-D ≥ 16) At 3 months G1: 2 G2: 1 At 6 months G1: 2 G2: 3 Combined G1: 4 G2: 4 Other HAM-D17 3 mos = P = NS, CI -1.83, 4.46; 6 mos = P = NS, CI -3.61, 4.61 ECT vs. rTMS BDI NR MADRS NR IDS NR CGI-S NR CGI-I No NR Baseline n NR Endpoint score, mean (SD) NR Achieving 1 or 2 score, %(SD) NR Other NR Other | Quality of Life Global Assessment of Functioning (GAF), or GAS Baseline n G1: 20 G2: 21 Baseline score, mean (SD) G1: 71.81 (10.39) G2: 72.50 (9.39) Endpoint score, mean (SD) At 3 months G1: 75.52 (13.81) G2: 79.75 (12.92) At 6 months G1: 72.8 (11.94) G2: 77.75 (17.13) Change, mean (SD) At 3 months G1: -3.71 G2: -7.25 At 6 months G1: -0.99 G2: -5.25 Other 3 mos P = NS, CI -12.69, 4.23; 6 mos P = NS, CI -14.40, 4.50 Adverse Events NR Neuropsychological or executive functioning No Measures, Results NR Predefined NA - No AE data reported MMSE NR Attrition Overall, % 4.6% At end of treatment, % NR At end of followup, % G1: 0 G2: 9 Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % G1: NR G2: NR Other; - 43 people agreed to be part of study, two were dropped before final analysis, no explanation is given, and they are not included in final analysis.; - The Michigan Adequacy of Treatments (MATS) was also included in this study. MATS for ECT was 3 mos FU 1.92 (1.04 SD), 6 mos FU 1.82 (0.98 SD); rTMS 3 mos FU 2.28 (1.07 SD), 6mos 2.44 (1.03 SD). CI for 3 mos FU ECT vs. rTMS is -1.14 - 0.43, P = N; Adherence/ compliance NR

Evidence Table 12 KQ 4. Cognitive Functioning: Tier 1 (ECT vs. rTMS—MDD only)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Rosa et al, 2006^2^ Country, setting Brazil, university clinic, inpatients and outpatients included Funding Not reported Research Objective To Compare efficacy and side effects associated with rTMS and ECT in an adult population with TRD Quality Rating Fair | Study design RCT Type of analysis Included completers analysis & ITT (LOCF), ITT is reported in abstraction N 42 Duration Active txt 2-4wks (rTMS pts not responding after 2 wks switched over to ECT), Primary Outcome: HAM-D response at 4wk Interventions G1: ECT G2: rTMS Medications allowed ADs, antipsychotics, mood stabilizers were discontinued while anti-anxiety meds were allowed/initiated as needed Strategy Switch Parameters rTMS:; - Frequency (Hz):10; - Motor threshold (%): 100; - Number of trains: 25; - Length of train (seconds): 10; - Inter-train interval: 20; - Pulses per session: 2500; - Total number of sessions: 20 over 4 wks; ECT:; - % receiving bilateral: NR; - Intensity: 4.5 times threshold; - Number of sessions (range, mean, SD): 10 (1.5) | TRD definition; - A lack of response to at 2+ antidepressants of different classes used for at least 4 wk with adequate dosages, with augmentation (with lithium or thyroid hormone for at least 1 trial); - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - Age 18-65; - unipolar depressive disorder (Ham-D >=22) w/o psychotic symptoms; Exclusion criteria; - History of epilepsy, neurosurgery with presence of metal clips, other neurological or psychiatric disease; - Use of cardiac pacemaker; - Pregnancy | Treatment Failure Previous treatment, not specified, % Overall:100% Polarity, % Unipolar Overal: 100% Age, mean yrs G1: 46.0 G2: 41.8 Sex, % females G1: 46.7 G2: 60.0 Race, % white G1: 80.0 G2: 90.0 HAM-D 17 Baseline n G1: 20 G2: 22 Baseline score, mean (SD) G1: 32.1 (5.0) [based on completers N = 15] G2: 30.1 (4.7) [N = 20] CGI Baseline n G1: 20 (N analyzed =15) G2: 22 (N analyzed =20) Baseline score, mean (SD) G1: 4.7 (0.8) G2: 4.3 (0.8) | HAM-D 17 Endpoint score, mean (SD) NR (graph only) Change, mean (SD) NR (graph only) P = 0.86 Responders, n (%) G1: 6 (20) G2: 10 (45) P = 0.35 Remitters, n (%) Ham-D17 <= 7 G1: 3 (15) G2: 2 (9) P = 0.65 Instrument CGI Endpoint score, mean (SD) 2wk G1: 4.0 (1.0) G2: 3.7 (1.1) 4wk G1: 3.2 (1.5) G2: 3.1 (1.3) Change, mean (SD) NR, P = 0.672 | Quality of Life NR Adverse Events Overall, % NR Suicidality, % G1: 10.0 G2: 9.1 rTMS: 2 pts developed new psychological symptoms (i.e. 1 = dissociative state, 1 = hypomanic symptoms) and were removed from study Neuropsychological or executive functioning NS differences between groups on all neuropsychological tests following wk2 & wk4. (Weschler Adult Intelligence Scale - R subtests (Vocabulary, Cube) Wechsler Memory Scale subtest (Digit Span) Rivermead Behavioral Memory Test) MMSE NR Other Attrition Overall, % 16.7 At end of treatment, % G1: 15.0* G2: 9.1* *Prior to completing txt (txt end date differed by pt) At end of follow-up, % G1: 25.0 G2: 9.1 Withdrawals due to efficacy, % G1: NR G2: 0.0 Withdrawals due to adverse events, % G1: NR G2: 9.1 Other For ECT, 3 were removed by their treating clinician w/o explanation or evaluation of efficacy Adherence/ compliance NR
Author, Year Schulze-Rauschenbach et al., 2005^63^ Country, setting Germany, Psychiatric University Hospital, inpatients Funding NR Research Objective To compareneurocognitive effects of unilateral ECT and rTMS using a control Quality Rating Fair | Study design Observational Type of analysis Observational study of patients completing txt N 30 Duration Not clear- testing took place 8.8 days on average afterlast treatment Estimated duration from mean number of txt – ECT 5 weeks and rTMS 3-5 weeks. Interventions Control G1: ECT G2: rTMS Medications Allowed Antidepressants, low-potency neuroleptics and non-benzodiazepine hypnotics were allowed in both groups. No med changes allowed during study Parameters ECT:; - % receiving bilateral: 0; - Intensity: 2.0-2.5 times seizure threshold; - Number of sessions (range, mean, SD): 9.9 (2.7); rTMS; - Frequency (Hz): 10; - Motor threshold (%): 100; - Number of trains: 20-30; - Length of train (seconds): 2; - Inter-train interval: 5; - Pulses per session: 400-600; - Total number of sessions: 2-3/wk; Strategy Augment or add-on | TRD definition; - Unsuccessful treatment response to at least two different types of antidepressants, each given in a sufficient dosage range for at least 4 weeks; - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - Consecutively admitted patients with DSM–IV diagnosis of MDD; - Age over 18 years; Exclusion criteria; - Previous treatment with ECT or rTMS; - Additional Axis I diagnosis | Treatment Failure Mean failed trials NR Polarity, % Unipolar 100% MDD Age, mean yrs G1: 46.7 G2: 47.7 Sex, % females G1: 50 G2: 44 HAM-D 17 Baseline n G1: 14 G2: 16 Baseline score, mean (SD) G1: 22.4 (3.1) G2: 21.3 (3.5) BDI Baseline n G1: 14 G2: 16 SSMQ Baseline n G1: 14 G2: 16 Baseline score, mean (SD) G1: -20.7 (19.0) G2: -16.8 (16.9) | HAM-D 17 Endpoint score, mean (SD) G1: 14.5 (5.7) G2: 13.0 (4.9) Change, mean (SD) G1: -7.9 G2: -8.3 Group × time, P = NS Responders, n G1: 6 (46%) G2: 7 (44%) P = 0.90 BDI Change, mean (SD) G1: 7.6 G2: 6.4Group × time, P = NS SSMQ Endpoint score, mean (SD) G1: -15.2 (25.2) G2: 3.8 (11.8) Change, mean (SD) G1: 5.5 G2: 20.6 | Quality of Life NR Adverse Events One patient in ECT group withdrew due to severe orientation and memory problems following two treatments; data not included. Neuropsychological or executive functioning Test scores; - ECT Pre / Post vs. rTMS Pre / Post Post; P = Post Ect vs. Post rTMS; - Learning and anterograde memory; AVLT; - Immediate recall (trials 1-5); P = NS; - Recall after interference (trial 5 minus trial 6) 2.8 (2.2) / 3.9 (1.9) vs. 3.2 (1.9) / 1.8 (2.0); P < 0.01; - Recall after delay (trial 5 minus trial 7) 2.4 (1.8) / 4.2 (1.6) vs. 3.2 (1.6) / 2.4 (2.0); P < 0.05; - Recognition hits; P = NS and Recognition false alarms; P = NS; MPT; - Recall trial; P = NS and Delayed recall; P = NS; Retrograde memory Retrograde AVLT; - Recall; P = NS and Recognition hits; P = NS; - Recognition false alarms 5.0 (3.0) vs. 1.1 (1.1); P < 0.05; Four-card task; - Free recall 0.4 (0.5) vs. 1.4 / (1.2); P < 0.05; - Recognition; P = NS; - AMI Recall score; P = NS; Subjective memory; - SSMQ -20.7 (19.0) / -15.2 (25.2) vs. -16.8 (16.9) / 3.8 (11.8); P < 0.05; Other cognitive functions; - MMSE; P = NS, TrailMakingTest A; P = NS, TrailMakingTest B; P = NS, Digit span (WAIS-R); P = NS, Letter-number span; P = NS, Word fluency (LPS); P = NS; MMSE G1: ECT G2: rTMS G3: Control Baseline n G1: 14 G2: 16 G3: 15 Baseline score, mean (SD) G1: 27.9 (1.7) G2: 26.9 (3.4) G3: 29.1 (1.0) Endpoint score, mean (SD) G1: 28.3 (1.3) G2: 27.9 (3.0) G3: 29.2 (1.1) Change, mean (SD) G1: 0.4 G2: -1 G3: 0.01 Other P = NS Attrition Overall, % 3.3 At end of treatment, % G1: 7 G2: 0 At end of follow-up, % G1: NR G2: NR Withdrawals due to efficacy, % G1: 0 G2: 0 Withdrawals due to adverse events, % G1: 7 G2: 0 One person in ECT group withdrew because of severe orientation and memory problems after 2 ECT treatments; these data were not included inanalysis Adherence/ compliance NR

Evidence Table 13 KQ 4. Cognitive Functioning: Tier 1 (rTMS vs sham—MDD only)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Avery et al., 2006^10^ Country, setting USA, Single center, University department of psychiatry, outpatient Funding NIMH Research Objective To test hypothesis that patients receiving active TMS would show a greater antidepressant response rate than those receiving sham stimulation Quality Rating Good Fair for KQ2 and subgroups11 (small number of people followed for relapse; used a single measure and did not account for additional medical conditions) | Study design RCT Type of analysis ITT N 68 Duration 4 weeks (15 sessions) of txt, primary assessment 1 week after completion of txts. Responders were evaluated for relapse 2 wks after primary endpoint Interventions G1: High-left TMS G2: Sham Medications Allowed; - Pts encouraged, although not required, to discontinue current antidepressant medication, sedatives, or benzodiazepines; (continuing AD medication G1: 31% vs. G2: 27%; continuing benzodiazapines G1: 26% vs. G2: 24; - Those stopping medications had to be medication-free for at least 2 weeks; - All responders given AD post rTMS treatment (active or sham); Strategy Mixed-within group differences Parameters rTMS; - Frequency (Hz):10; - Motor threshold (%): 110; - Number of trains: 32; - Length of train (seconds): 5; - Inter-train interval: 25-30; - Pulses per session: 1600; - Total number of sessions: 15 in 4 wks; Sham; - Identical stimulation parameters; - Lateral edgeof coil rotated 90° away from scalp | TRD definition; - Failed to respond to or unable to tolerate at least 2+ adequate AD trials (defined by score ≥3 on ATHF); - Failures not required to be in current episode; Tier 1 Inclusion criteria; - TRD; - 21 to 65 years old; - DSM-IV criteria for current major depressive disorder (MDD); - HAM-D 17 ≥ 17 and a decrease of no more than 20% between screening and 1st txt day; Exclusion criteria; - Previous TMS exposure; - Bipolar disorder; - Previous failure of nine or more bitemporal ECT treatments; - Current major depressive episode longer than 5 years; - History of substance abuse or dependence withinpast 2 years,; - Antisocial or borderline personality disorder,; - Active suicidal ideation; - Vurrent symptoms of psychosis,; - Hx of seizure disorder,; - Hx of closed head injury with loss of consciousness or prior brain surgery; - Any other major psychiatric or medical comorbidity | Subgroups Pain, subgroup analysis presented in Avery et al, 2007^11^ Baseline n G1: 35 G2: 33 Treatment Failure Current episode failures, mean (SD) G1: 1.46 (0.78) G2: 1.48 (0.67) Mean failed trials (SD) G1: 3.2 (2.44) G2: 3.3 (1.72) Polarity, % Unipolar 100 Age, mean yrs G1: 44.3 G2: 44.2 Sex, % females G1: 60 G2: 52 Race, % white NR Right handed, % NR Groups similar at baseline Yes HAM-D 17 Baseline score, mean (SD) G1: 23.5 (3.9) G2: 23.5 (2.9) BDI Baseline score, mean (SD) G1: 28.1 (8.7) G2: 28.4 (8.0) | HAM-D 17 Endpoint score, mean (SD) G1: 15.7 G2: 19.8 Change, mean (SD) G1: -7.8 (7.8) G2: -3.7 (6.3) Group × time P = 0.002 Responders, n G1: 11 (31.4%) G2: 2 (6.1%) P = 0.008 Remitters, n HAM-D21 < 10 G1: 7 (20.0%) G2: 1 (3.0%) P = 0.033 No Relapse (at 6mos), N G1: 5 G2: Unknown (1 relapsed, 1 loss to follow after 3 mos of without relapse) BDI Change, mean (SD) G1: 11.3 (12.8) G2: 4.8 (8.5) Random Regression analyses revealed significant group by time interaction (P = 0.003) | Quality of Life NR Adverse Events Overall, % NR Site pain first session sham none (0/33) vs. TMS group, 41% (14/35)15th session sham 3% (1/30) vs. TMS 33% (11/33). The discomfort pain scale ratings (0-4) decreased inTMS group in subsequent treatment sessions, decreasing from a mean of 1.89 ( 1.02) at session 1 to 1.11 ( 1.03) at session 15 (t = 4.24, P < 0.001). Changes from baseline in128 individual SAFTEE scores -emerging symptoms were analyzed by chi-square analyses at visits 5, 10, 15, and 16 with a Bonferroni correction, there were no significant differences between TMS and sham in any ofemerging symptoms. (Data = NR) Neuropsychological or executive functioning No sig differences in GOAT, RAVLT, WAIS-R, COWAT, and SAFTEE; SUBGROUP ANALYSIS11: At 15th session pain TMS 33% vs, sham 3% (P < 0.05) no statistically significant (P > 0.05) time by treatment group interactions for any of neuropsychological test measures., There was significant improvement in individual neuropsychological test performances for both groups. No confusion was associated withTMS treatments.GOAT assessments were well within normal range and ranged from 98 to 100. No significant (P > 0.05) differences between groups for any session. MMSE NR Attrition Overall, % 7.4% (5/68) At end of treatment, % NR At end of follow-up, % NR Withdrawals due to efficacy, % G1: 0 G2: 3.0 Withdrawals due to adverse events, % G1: 0 G2: NR Very unclear as to when patients discontinued Adherence/ compliance NR
Author, Year Holtzheimer et al., 2004^19^ Country, setting USA, single center, outpatient/inpatient status not clearly stated Funding University of Washington Research Objective Initial hypotheses that rTMS would have greater antidepressant effects than sham stimulation and that rTMS would be safe and tolerable Quality Rating Fair | Study design RCT Type of analysis ITT N 15 Duration Primary endoint following 2 weeks of treatment and follow-up 1 week after txt completed Interventions G1: rTMS G2: Sham Medications Allowed All pts discontinued (failed) AD medication Strategy Switch Parameters rTMS; - Frequency (Hz): 10; - Motor threshold (%): 110; - Number of trains:32; - Length of train (seconds): 5; - Inter-train interval: 30-60; - Pulses per session: 1600; - Total number of sessions: 10 over 2 wks; Sham rTMS; - Delivered in same anatomical location with identical stimulation parameters, but with lateral edge of coil rotated 45 degrees away from scalp | TRD definition; - Subjects must have failed at least 2 previous antidepressant trials due to lack of response to adequate trial (defined by ATHF) or medication intolerance; - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - 21 to 65 years of age; - Right-handed; - Meet DSM-IV criteria for a major depressive episode due to MDD; - HAM-D17 ≥ 18; Exclusion criteria; - No other major psychiatric or medical comorbidity; - History of Bipolar Disorder; - Previous failure of ECT; - History of substance abuse or dependence; - Current symptoms of psychosis; - Pregnancy | Treatment Failure Failed 7 or more, % G1: 85.7 G2: 37.5 Polarity, % Unipolar 100% MDD Age, mean yrs G1: 40.4 G2: 45.4 Sex, % females G1: 57.1 G2: 42.9 Right handed, % G1: 100 G2: 100 HAM-D 17 Baseline n G1: 7 G2: 8 Baseline score, mean (SD) G1: 22.7 (5.3) G2: 20.8 (6.3) BDI Baseline score, mean (SD) G1: 29.6 (10.0) G2: 28.5 (10.6) | HAM-D 17 Endpoint score, mean (SD) At week 1 G1: 18.0 (1.2) G2:18.0 (2.7) At week 2 G1: 14.6 (3.2) G2: 15.3 (3.0) 1 week follow-up G1: 18.8 (2.5) G2: 17.6 (2.1) Change, mean (SD) At week 1 G1: 4.7 G2: 2.8 At week 2 G1: 8.1 G2: 5.5 1 week follow-up G1: 3.9 G2: 3.2 All endpoints, P = NS Responders, n (%) At week 1 G1: 0 G2: 0 At week 2 G1: 2 (28.6) G2: 1 (12.5) 1 week follow-up G1: 0 G2: 0 BDI Endpoint score, mean (SD) At week 1 G1: 27.5 (3.2) G2: 24.9 (2.7) At week 2 G1: 23.9 (2.6) G2: 22.4 (2.4) 1 week follow-up G1: 23.9 (1.6) G2: 26.4 (1.9) Change, mean (SD) At 2 weeks G1: 5.7 G2: 6.1 Change, mean (SD) 1 week follow-up G1: -5.7 G2: -2.1 Group × time (all points), P = NS | Quality of Life NR Adverse Events No major adverse events at any point in study. Some subjects experienced mild pain withactive rTMS, but treatments were generally well tolerated. Neuropsychological or executive functioning Both groups performed equally well withexception of one measure of verbal memory, Trial 7 ofRey Auditory Verbal Learning Test, in which subjects that received rTMS performed slightly better (rTMS: mean score = 12.7 (2.1) vs.: sham mean score = 12.0 (2.3); P < 0.05). No acute changes in level of consciousness, orientation, or short-term memory associated with any rTMS or sham treatments sessions. MMSE NR There were no major adverse events at any point instudy. Some subjects experienced mild pain withactive rTMS, but treatments were generally well tolerated. Attrition Overall, % 0 during treatment. 3 (20%) beforefinal assessment at week 3 At end of treatment, % 0 At end of follow-up, % G1: 28.6 G2: 12.5 Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR Other NR Adherence/ compliance Compliance All 15 subjects completed all 10 txt sessions
Author, Year Padberg et al., 1999^21^ Country, setting Germany, university clinic, patient status not clear Funding Magstim Company Ltd. & Micromed Medizin-Elektronik GmbH Research Objective Compare antridepressant efficacy and tolerability of fast, slow, and sham rTMS in TRD Quality Rating Fair | Study design RCT Type of analysis ITT N 18 Duration 1 week of active txt Primary outcome: Change in HAM-D after 5 txt sessions Interventions B - Repetetive Transcranial Magnetic Stimulation (rTMS)E - Placebo G1: Fast rTMS G2: SlowrTMS G3: Sham rTMS Medication allowed 83.3% of pts continued on their current [failed] AD medication,others were not on a med and did not start one prior to trial Strategy Augmentation Parameters rTMS High; - Frequency (Hz):10; - Motor threshold (%): 90; - Number of trains: 5; - Length of train (seconds): 5; - Inter-train interval: 30; - Pulses per session: 250; - Total number of sessions: 5/wk; rTMS Low; - Frequency (Hz):0.3; - Motor threshold (%): 90; - Number of trains: 10; - Length of train (seconds): 25; - Inter-train interval: NR; - Pulses per session: 75; - Total number of sessions: 5/wk; Sham:; - Same as high rTMS except coil angled at 90 degrees with 1 wing resting on skull | TRD definition; - 2+ failed txt trials of 4+ wks duration including at least 1 tricyclic; - Required to be in current episode; Tier 1 Inclusion criteria MDD (DSM IV) Exclusion criteria Organic brain disorders, contraindications for rTMS | Treatment Failure Current episode failures, mean G1: 4.0 (2.2) G2: 3.2 (0.8) G3: 3.2 (1.2) Polarity, % Unipolar 100 Age, mean yrs G1: 63.5 G2: 46.7 G3: 43.3 Sex, % females G1: 33.3 G2: 83.3 G3: 66.7 Right handed, % G1: 100 G2: 100 G3: 100 HAM-D 21 Baseline n G1: 6 G2: 6 G3: 6 Baseline score, mean (SD) G1: 30.2 (9.5) G2: 26.7 (9.4) G3: 22.2 (8.8) MADRS Baseline n G1: 6 G2: 6 G3: 6 Baseline score, mean (SD) graph only | HAM-D 21 Endpoint score, mean (SD) G1: 28.5 (9.4) G2: 21.5 (21.5) G3: 23.5 (10.4) Change, mean (SD) G1: -1.7 G2: -5.2 G3: -1.3 P > 0.05 Responders, n NR Remitters, n NR MADRS Endpoint score, mean (SD) graph only Group × time, P < 0.1 | Quality of Life NR Adverse Events Headache, % G1: 16.7 G2: 16.7 G3: NR Focal Pain at rTMS site during stimulations, %: G1: 50 G2: 33.3 G3: 0 There were no serious AE. Neuropsychological or executive functioning Verbal Memory Tests (included 3 learning trials and a consecutive, delayed recall task after distraction): Verbal memory performance improved significantly after fast rTMS Learning; 1. P = 0.006; 2. NA; 3. Fast rTMS; improvement P = 0.032, Slow rTMS P = NS, Sham decrease in performance P = 0.09 MMSE NR Attrition Overall, % NR, “no pts asked for discontinuation of rTMS” At end of treatment, % NR At end of follow-up, % NR Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR Adherence/ compliance NR - “compliance was excellent”

Evidence Table 14 KQ 4. Cognitive Functioning: Tier 1 (rTMS vs sham—MDD/Bipolar)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Fitzgerald et al., 2003^15^ Country, setting Australia 2 general psychiatric services, outpatients Funding National Health and Medical Research Council and a grant fromStanley Medical Research Institute Research Objective To evaluate efficacy of HFL-TMS and LFR-TMS in treatment-resistant depression and compared with a sham-treated control group Quality Rating Fair | Study design RCT Type of analysis ITT N 60 Tier 1 Duration Primary endpoint after 2 weeks of txt, after which pts with <20% reduction in MADRS could cross over to the other active txt. Follow-up assessment conducted at 2 weeks post txt. Interventions G1: High Frequency rTMS G2: Low Frequency rTMS G3: Sham Medications Allowed 46 patients continued (failed) AD medication while others were not on a med at study entry. Patients allowed mood stabilizers and antipsychotics Strategy Augmentation Parameters rTMS LowFrequency (Hz):1; - Motor threshold (%): 100; - Number of trains: 60; - Length of train (seconds): 5; - Inter-train interval:60; - Pulses per session: 300; - Total number of sessions: 10 sessions daily, 5 days/week; rTMS High; - Frequency (Hz):10; - Motor threshold (%): 100; - Number of trains: 20; - Length of train (seconds): 5; - Inter-train interval: 25; - Pulses per session: 1000; - Total number of sessions: 10 sessions daily, 5 days/week; Sham rTMS; - Coil angled 45 degrees offhead for 10 sessions daily, 5 days/week | TRD definition; - Failed a minimum of 2 courses of antidepressant medications (6+ weeks); Not required or not specified to be in current episode Inclusion criteria; - DSM-IV diagnosis of Major Depression (included bipolar depression); Exclusion criteria; - Significant medical illnesses, neurologic disorders, or other Axis I psychiatric disorders | Treatment Failure Mean failed trials Overall (SD) 5.68 (3.40) Polarity, % Bipolar I G1: 5 G2: 5 G3: 20 Age, mean yrs G1: 42.2 G2: 45.55 G3: 49.15 Sex, % females G1: 40 G2: 35 G3: 55 Right handed, % G1: 90 G2: 100 G3: 85 BDI Baseline n G1: 20 G2: 20 G3: 20 Baseline score, mean (SD) G1: 33.15 (12.12) G2: 35.05 (9.25) G3: 32.30 (9.10) MADRS Baseline n G1: 20 G2: 20 G3: 20 Baseline score, mean (SD) G1: 36.05 (7.55) G2: 37.70 (8.36) G3: 35.75 (8.14) | BDI Endpoint score, mean (SD) At 2 weeks G1: 26.7 (11.9) G2: 27.2 (10.8) G3: 29.0 (8.7) Change, mean (SD) At 2 weeks G1:- 6.4 G2: -7.8 G3: -2.3 P = 0.03 MADRS Endpoint score, mean (SD) At 2 weeks G1: 30.8 (7.8) G2: 32.2 (9.0) G3: 35.4 (7.5) Change, mean; % change, (SD) At 2 weeks G1: -5.25; 13.5 % (16.7%) G2: -5.5; 15.0% (14.1%) G3: -0.35; 0.76% (16.2%) P = 0.004 G1: vs. G3, G2 vs. G3, P < 0.005 Responders, n 20% ≤ decrease At 2 weeks G1: 8 (40) G2: 7 (35) G3: 2 (10) P = 0.07 Responders, n 50% ≤ decrease At 2 weeks G1: 0 G2: 1 (5) G3: 0 P = NR CGI Endpoint score, mean (SD) NR P = 01 | Quality of Life GAF Global Assessment of Functioning Baseline n G1: 20 G2: 20 G3: 20 Baseline score, mean (SD) G1: 43.00 (6.76) G2: 43.55 (9.94) G3: 42.75 (7.15) Endpoint score, mean (SD) At 2 weeks G1: 45.2 (7.1) G2: 46.3 (8.5) G3: 42.5 (6.8) Change, mean (SD) At 2 weeks G1: 2.2 G2: 2.85 G3: 0.5 Overall group F56,2=2.6; P =.08; LFR-TMS vs sham: P = 0.03; and HFLTMS vs sham: P = 0.09 Quality of Life Overall group F56,2=2.6; P =.08; LFR-TMS vs sham: P = 0.03; and HFLTMS vs sham: P = 0.09 Adverse Events Dizziness, % G1: 5% G2: 5% G3: 0 G4: 3.3% Other: 0- 2wks:; - 7 (11%) of 60 patients reported site discomfort or pain during rTMS and 6 (10%) reported a headache after rTMS.; - Although there was no difference in incidence of these adverse effects (P =.08), patients inHFL-TMS group seemed to report more discomfort during procedure itself.; - Only 1 patient ( HFL-TMS group) reported persistence ofheadache for longer than 1 hour.; - Two patients (1 in each group) reported transient dizziness for a short time after treatment.; 2wks - 4 wks:; - One patient withdrew after 1 session of HFL-TMS treatment insingle-blind phase ofstudy owing to site pain.; - One bipolar patient, who had a successful response to LFR-TMS treatment, experienced a manic episode 10 days after completion of trial after ceasing treatment with valproate sodium; Neuropsychological or executive functioning; - No deterioration in performance was found in any cognitive; - Including all patients who underwent at least 1 type of active treatment, there was a significant improvement in performance on verbal paired associates (t50=−7.3; P < 0.001), verbal fluency (t48=−3.8; P < 0.001), and digit span forwards (t48=−1.8; P = 0.003) subscales;Personal Semantic Memory Schedule (t50=−2.4; P = 0.02); andAutobiographical Memory Schedule (t50=−1.9; P = 0.05).; - A similar pattern of improvements was seen for each of; - treatment subgroups (HFL-TMS only, LFR-TMS only, or both active treatments).; - Changes in performance on cognitive measures did not correlate with changes in MADRS and Beck Depression Inventory scores across sametimes.; MMSE NR Other Attrition Overall, % None in initial 2 week treatment phase At end of treatment, % 0 At end of follow-up, % NR But at least 28.3% did not continue on through 2nd 2 weeks Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % G1: 0 (1 during follow-up) G2: 0 (0 during follow-up) G3: 0 (0 during follow-up) Progression of patients through 2nd phase is very unclear Adherence/ compliance NR

Evidence Table 15 KQ 4. Cognitive Functioning: Tier 2 (rTMS vs. sham—MDD only)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Manes et al., 2001^29^ Includes additional neuro-psychological outcomes reported in Moser et al., 2002^30^ Country, setting US, outpatient clinic Funding NIMH Research Objective To examineantidepressant efficacy of rTMS in a TRD population Quality Rating Fair | Study design RCT Type of analysis cannot tell if ITT N 20 Duration 2 weeks (1 week of treatment, 1 wk follow-up following last treatment) Primary outcomes HAM-D at end of treatment and at 1 week follow-up Interventions G1: rTMS (N=10) G2: Sham rTMS (N=10) Medications allowed No antidepressant medication Strategy Switch Parameters rTMS; - Frequency (Hz):20; - Motor threshold (%): 80; - Number of trains: 20; - Length of train (seconds): 2; - Inter-train interval: 60; - Pulses per session: 800; - Total number of sessions: 5/wk; Sham:; - Same stimulation, figure 8 coil was above top of skull and handle was placed against head | TRD definition; - Not required or not specified to be in current episode; Setting(s) Outpatient Psychiatric Inclusion criteria; - Major/Minor Depression (DSM IV),; - TRD (1+ failed trial); Exclusion criteria NR | Subgroups Age 50+ Treatment Failure Mean failed trials G1: 4 (2.3) G2: 4 (1.2) Polarity, % Major Depression G1: 80 G2: 100 Dysthymia G1: 20 G2: 0 Age, mean yrs G1: 60.5 G2: 60.9 Sex, % females G1: 50 G2: 50 Race, % white G1: 100 G2: 100 HAM-D Baseline n G1: 10 G2: 10 Baseline score, mean (SD) G1: 22.7 (5.2) G2: 22.7 (7.1) | HAM-D Endpoint score, mean (SD) At 1 week G1: 13.7 (5.4) G2: 16.2 (8.5) 1 week Follow-up G1: 14.4 (6.4) G2: 15.5 (9.1) Change, mean (SD) At week 1 G1: -9 G2: -6.5 1 week follow-up G1: -8.3 G2: -7.2 All time points P >0.66; pts with MDD only - P = 0.3919 Responders, n (%) G1: 3 (30) G2: 3 (30) P = NS Remitters, n G1: 2 G2: 2 P = NR | Quality of Life NR Adverse Events Headache, % G1: 40% G2: 0% Other: Local pain/local discomfort: 10%/40% vs. 0%/40%; anxiety: 0 vs 10% Neuropsychological or executive functioning **30 (endpoint: mean of 3 days after 5 days of txt) Trail Making Test B score Baseline: rTMS: 87.22 Sham: 103.67 Follow-up rTMS: 58.59 Sham: 100.64 **some variation in pts included in two samples but reported as same study by authors. #1564 includes at least 1 participant <50 years old, n=19 Other neuropsychological tests showing no statistical significance in either group: Trail Making Test-A, Stroop Test, WAIS-R digit symbol, Controlled Oral Word Association, Boston naming test, stentance repitition, Rey Auditory Verbal Learning test, & Judgement of Line Orientation MMSE Baseline n G1: 10 G2: 10 Baseline score, mean (SD) G1: 28.7 (1.4) G2: 28.6 (1.3) Endpoint score, mean (SD) At Week 1 G1: 29.6(0.7)) G2: 29.3 (0.7) At Follow-up Week 1 G1: 29.6(1.8) G2: 29.2 (0.8) Change, mean (SD) NR; 1. P >0.41; 2. P = NA; 3. P = NR; Attrition NR Adherence/ compliance NR

Evidence Table 16 KQ 4. Cognitive Functioning: Tier 3 (ECT vs. rTMS—MDD/Bipolar)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year McLoughlin et al., 2007^7^ Eranti et al., 2007^8^ Knapp et al., 2008^9^ Country, setting UK, South London and Maudsley NHS Trust and Pembury Hospital inInvicta Mental Health Trust in Kent, 65.2% were inpatients Funding National Health Service Research and Development, National Coordinating Centre for Health Technology Assessment (NCCHTA) (98/11/04); by Guy's and St. Thomas's Charitable Foundation (R001126); and by a 2003 Ritter Independent Investigator Award from National Alliance for Research on Schizophrenia and Depression. Research Objective. To assess clinical effectiveness of rTMS vs. ECT for treating major depressiveepisodes in patients referred for ECT Quality Rating Good | Study design RCT- pragmatic and single blinded (raters) Type of analysis m-ITT N 46 Duration Primary endpoint at 3 weeks for rTMS and at clinicians discretion for ECT, additional follow-up at 6 months Interventions G1: ECT G2: rTMS Medication Allowed Patients continued their usual medical care and stable psychotropic medications were allowed (i.e. SSRIS, TCAs, Venlafaxine, Mirtazapine, Lithium, Anticonvulsant mood stabilizers, Benzodiazepines, Antipsychotics, Zopiclone, L-Tryptophan) Strategy Augmentation Parameters rTMS; - Frequency (Hz): 10; - Motor threshold (%):110; - Number of trains: 20; - Length of train (seconds): 5; - Inter-train interval: 55; - Pulses per session: 1000; - Total number of sessions:15; ECT:; - % receiving bilateral: 82; - Intensity: 1.5 × ST for bilateral frontotemporal ECT and 2.5 × ST for right unilateral ECT; - Number of sessions (range, mean, SD): range = 2-10, mean = 6.3, SD = 2.5 | TRD definition; - All patients referred for ECT:; - No failure required; Tier 3 Inclusion criteria; - Right handed patients; - more than 18 years old; - refered for ECT due to major depressive episode; Exclusion criteria; - Inability to have rTMS because of metallic implants or foreign bodies; - History of seizures; - Substance misuse in previous 6 months; - Being medically unfit for general anesthesia or ECT:; - ECT or rTMS in previous 6 months,; - Dementia or other axis I diagnosis; - Inability or refusal to provide informed consent. | Treatment Failure Mean failed trials G1: 2.5 (1.4) G2: 2.4 (1.0) Polarity, % MDD G1: 91.67 G2: 90.91 Bipolar G1: 8.33% G2: 9.09 % Age, mean yrs G1: 63.6 G2: 68.3 Sex, % females G1: 67.7 G2: 72.7 Right handed, % Overall: 100% HAM-D 17 Baseline n G1: 22 G2: 24 Baseline score, mean (SD) G1: 24.8 (5.0) G2: 23.9 (7.0) BDI: Baseline score, mean (SD) G1: 36 (8.7) G2: 37.8 (10.5) | HAM-D 17 Analyzed n G1: 22 G2: 23 Endpoint score, mean (SD) End of treatment G1: 10.7 G2: 18.5 P = 0.002, effect size of 1.44 Follow-up at 6 months G1: NR G2: NR P = 0.93 Change, mean (SD) End of treatment G1: -14.1 G2: -5.4 P = 0.017 Responders, n End of treatment G1: 13 (59.1%) G2: 4 (17.4%) P = 0.005 Remitters, n HAM-D ≤ 8 End ot treatment G1: 13 (59.1%) G2: 4 (17.4%) P = 0.005 Follow-up at 6 months* G1: 6 (27.4%) G2: 2 (8.7%) *only 12 ECT remitters followed after End of txt BDI Endpoint score, mean (SD) NR P = 0.01 effect size=0.9 Change, mean (SD) NR Group × time, P = 0.25 Responders, n NR Remitters, n NR | Quality of Life SF-36 mental health component score Baseline n G1: 24 G2: 22 Baseline score, mean (SD) G1: 48.9 (12.6) G2: 42.7 (7.5) Other: QALYs Six month QALY gain, mean (SD) G1: 0.0300 (0.053) G2: 0.0297 (0.056) (QALYs were derived using SF-36 data). At six month follow-up, service use data were collected on 28 pts (10-ECT and 18-rTMS). Patients responded much better to ECT than to rTMS by the end of the allocated treatment course. The differential QALY gain of treatment with rTMS over ECT was 0.0003 (p = 0.987). This suggests that treatment by rTMS does not provide any additional gains in quality of life over ECT over a 6-month period. The lack of a statistically significant difference in QALY gain between the two groups may reflect lack of difference in HRSD scores between groups at 6 months. Adverse Events NR Neuropsychological or executive functioning Predefined CAMCOG Attention and orientation subscale (max = 17): ECT baseline 12.8 (3.2), end of treatment 13.9 (3.6), 6mos 13.9 (3.5) rTMS baseline 14.7 (3.0) end of treatment 13.5 (3.3) FU6mos 13.4 (3.8), P = 0.004 No significant differences for rest of CAMCOG subscales (verbal fluency, anterograde memory, and retrograde memory) MMSE Baseline n G1: 16 G2: 22 Baseline score, mean (SD) G1: 24.3 (3.6) G2: 25.7 (3.9) Score at 6 months, mean (SD) G1: 25.4 (5.3) G2: 24.7 (4.8) Endpoint score, mean (SD) G1: 25.6 (3.9) G2: 24.4 (5.3) Change, mean (SD): G1: 1.3 G2: -1.3 P < 0.08 No significant differences on the Columbia ECT Subjective Side Effects Schedule for self-reported cognitive side effects. Attrition Overall to end of treatment 6/46, at 6 months 9/46 At end of treatment, % G1: 6/24 G2: 0 At end of follow-up, % NR Withdrawals due to efficacy, % G1: 5/24 G2: 0 Withdrawals due to adverse events, % 0 Adherence/ compliance NR
Author, Year O'Connor, 2003^64^ Country, setting United States, University Hospital, inpatient vs. outpatient population not clearly reported Funding NIH/NIMH and a NARSAD grant Research Objective Two procedures for treating major depressive disorder were compared with regard to their respective effects on mood and cognition Quality Rating Fair | Study design Observational Type of analysis Completers N 28 Duration; - Primary outcome at end of treatment (ECT applied for 2 to 4 weeks and rTMS a period of 2 weeks).; - Patients assessed for follow-up 2 weeks post txt; Medications allowed rTMS patients completed a washout of all psychotropic medications while ECT continued all medications Strategy Switch strategy for rTMS and augment or add-on strategy for ECT group Interventions G1: ECT G2: rTMS Parameters ECT; - % receiving bilateral:0; - Intensity: 2.5 times seizure threshold; - Number of sessions (range, mean, SD): 6-12, 3/wk; rTMS; - Frequency (Hz):10; - Motor threshold (%): 90; - Number of trains: 20; - Length of train (seconds): 8; - Inter-train interval: 24; - Pulses per session: 1600; - Total number of sessions:5/wk over 2wks | TRD definition; - Patients referred for ECT; - AD failures not required; Tier 3 Inclusion criteria; - Met criteria for MDD; - HRSD > 18; Exclusion criteria; - Psychosis, acute suicidality, other current Axis I diagnoses in DSM IV; - known CNS pathology, pacemakers, electronic or metallic implants, severe cardiac pathology; - personal or first degree family history of a seizure disorder; - inability to give informed consent | Treatment Failure Mean failed trials NR Polarity, % 100% MDD Age, mean yrs G1: 48.4+/- 12.0 G2: 51.2 +/- 12.2 HAM-D Baseline n Completers G1: 14 G2: 14 Baseline score, mean (SD) G1: 38.07 (8.1) G2: 29.3 (4.9) P = 0.001 Wechsler Memory Scale-III (WMS-III)-Letter Number Sequencing subtest Baseline n G1: 14 G2: 14 Baseline score, mean (SD) G1: 10.92 (2.49) G2: 10.42 (3.0) | HAM-D Endpoint score, mean (SD) End of treatment G1: 15.3 (11.7) G2: 25.6 (7.7) Follow-up 2 weeks G1: 20.4 (9.5) G2: 24.8 (9.5) Change, mean (SD) End of treatment G1: -23.7 G2: -3.73 Group × time P < 0.01 Responders, n G1: NR G2: 0 Remitters, n G1: NR G2: 100% Other Validated measure Yes Wechsler Memory Scale-III (WMS-III)-Letter Number Sequencing subtest Endpoint score, mean (SD) G1: 9.23 (1.83) G2: 10.71 (3.83) Change, mean (SD) At two weeks ECT scores on LN based on completers per protocol (n=13). ECT pts did not demonstrate a significant change in LN performance compared directly with2 week follow-up results (P > 0.05) No significant interaction between treatment sessions and groups with respect to LN (P > 0.05) | Quality of Life Adverse Events NR Neuropsychological or executive functioning Rey Auditory Verbal Learning Test-RAVLT (15 item word list to test new learning) Baseline n G1: 14 G2: 14 Baseline score, mean (SD) G1: 43.78 (11.07) G2: 43.71 (12.09) Endpoint score, mean (SD) G1: 29.14 (7.93) G2: 43.00 (10.00) Change, mean (SD) G1: 46.92 (10.80)/Difference between baseline acquisition and performance on acquisition task during 2-wk f/u session was not significant: P > 0.05 G2: 44.07 (10.43) RAVLT, Acquisition, mean (SD) Baseline: ECT 43.78 (11.07) vs. rTMS 43.71 (12.09). End of treatment: ECT 29.14 (7.93) vs. rTMS 43.00 (10.09) P < 0.01. Two weeks later: ECT 46.92 (10.80) vs. rTMS 44.07 (10.43) P > 0.05. RAVLT, Retention,(15-item word list after a 20-minute delay interval), mean (SD) Baseline ECT 8.07 (4.49) words vs. rTMS 9.76 (3.08) End of treatment ECT 2.14 ( 1.99) vs. rTMS 8.23 (2.80) Two weeks later, ECT 8.92 (4.14) vs. rTMS 8.31 (4.07). Transient News Events Test (TNET-measure of retrograde memory) Baseline n G1: 14 G2: 14 Baseline score, mean (SD) G1: 64.30 (19.40) G2: 55.62 (18.12) Endpoint score, mean (SD) G1: 39.10 (13,.21) G2: 57.81 (18.33) Change, mean (SD) G1: 59.20 (20.67) G2: 61.54 (19.12) Other Main-effect-of-group (P > 0.05). There was evidence of a significant interaction b/t txt grp and txt session: P < 0.001. Cognitive function/memory impairment reported as primary outcome measures. MMSE NR Attrition Overall, % No attrition At end of treatment, % NR At end of follow-up, % NR Withdrawals due to efficacy, % 0 Withdrawals due to adverse events, % 0 Adherence/ compliance NR

Evidence Table 17 KQ 4. Adverse Events : Tier 1 (rTMS vs. sham—MDD only)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Avery et al., 2006^10^ Country, setting USA, Single center, University department of psychiatry, outpatient Funding NIMH Research Objective To test hypothesis that patients receiving active TMS would show a greater antidepressant response rate than those receiving sham stimulation Quality Rating Good Fair for KQ2 and subgroups11 (small number of people followed for relapse; used a single measure and did not account for additional medical conditions) | Study design RCT Type of analysis ITT N 68 Duration 4 weeks (15 sessions) of txt, primary assessment 1 week after completion of txts. Responders were evaluated for relapse 2 wks after primary endpoint Interventions G1: High-left TMS G2: Sham Medications Allowed; - Pts encouraged, although not required, to discontinue current antidepressant medication, sedatives, or benzodiazepines; (continuing AD medication G1: 31% vs. G2: 27%; continuing benzodiazapines G1: 26% vs. G2: 24%); - Those stopping medications had to be medication-free for at least 2 weeks; - All responders given AD post rTMS treatment (active or sham); Strategy Mixed-within group differences Parameters rTMS; - Frequency (Hz):10; - Motor threshold (%): 110; - Number of trains: 32; - Length of train (seconds): 5; - Inter-train interval: 25- 30; - Pulses per session: 1600; - Total number of sessions: 15 in 4 wks Sham; - Identical stimulation parameters; - Lateral edgeof coil rotated 90° away from scalp | TRD definition; - Failed to respond to or unable to tolerate at least 2+ adequate AD trials (defined by score ≥3 on ATHF); - Failures not required to be in current episode; Tier 1 Inclusion criteria; - TRD; - 21 to 65 years old; - DSM-IV criteria for current major depressive disorder (MDD); - HAM-D 17 ≥ 17 and a decrease of no more than 20% between screening and 1st txt day; Exclusion criteria; - Previous TMS exposure; - bipolar disorder,; - previous failure of nine or more bitemporal ECT treatments; - current major depressive episode longer than 5 years; - history of substance abuse or dependence withinpast 2 years,; - antisocial or borderline personality disorder,; - active suicidal ideation; - current symptoms of psychosis,; - Hx of seizure disorder,; - Hx of closed head injury with loss of consciousness or prior brain surgery; - any other major psychiatric or medical comorbidity | Subgroups Pain, subgroup analysis presented in Avery et al, 2007^11^ Baseline n G1: 35 G2: 33 Treatment Failure Current episode failures, mean (SD) G1: 1.46 (0.78) G2: 1.48 (0.67) Mean failed trials (SD) G1: 3.2 (2.44) G2: 3.3 (1.72) Polarity, % Unipolar 100 Age, mean yrs G1: 44.3 G2: 44.2 Sex, % females G1: 60 G2: 52 Race, % white NR Right handed, % NR Groups similar at baseline Yes HAM-D 17 Baseline score, mean (SD) G1: 23.5 (3.9) G2: 23.5 (2.9) BDI Baseline score, mean (SD) G1: 28.1 (8.7) G2: 28.4 (8.0) | HAM-D 17 Endpoint score, mean (SD) G1: 15.7 G2: 19.8 Change, mean (SD) G1: -7.8 (7.8) G2: -3.7 (6.3) Group × time P = 0.002 Responders, n G1: 11 (31.4%) G2: 2 (6.1%) P = 0.008 Remitters, n HAM-D21 < 10 G1: 7 (20.0%) G2: 1 (3.0%) P = 0.033 No Relapse (at 6mos), N G1: 5 G2: Unknown (1 relapsed, 1 loss to follow after 3 mos of without relapse) BDI Change, mean (SD) G1: 11.3 (12.8) G2: 4.8 (8.5) Random Regression analyses revealed significant group by time interaction (P = 0.003) | Quality of Life NR Adverse Events Overall, % NR Site pain first session sham none (0/33) vs. TMS group, 41% (14/35)15th session sham 3% (1/30) vs. TMS 33% (11/33). The discomfort pain scale ratings (0-4) decreased inTMS group in subsequent treatment sessions, decreasing from a mean of 1.89 ( 1.02) at session 1 to 1.11 ( 1.03) at session 15 (t = 4.24, P < 0.001). Changes from baseline in128 individual SAFTEE scores -emerging symptoms were analyzed by chi-square analyses at visits 5, 10, 15, and 16 with a Bonferroni correction, there were no significant differences between TMS and sham in any ofemerging symptoms. (Data = NR) Neuropsychological or executive functioning No sig differences in GOAT, RAVLT, WAIS-R, COWAT, and SAFTEE; SUBGROUP ANALYSIS11: At 15th session pain TMS 33% vs, sham 3% (P < 0.05) no statistically significant (P > 0.05) time by treatment group interactions for any of neuropsychological test measures.There was significant improvement in individual neuropsychological test performances for both groups. No confusion was associated withTMS treatments.GOAT assessments were well within normal range and ranged from 98 to 100. No significant (P > 0.05) differences between groups for any session. MMSE NR Attrition Overall, % 7.4% (5/68) At end of treatment, % NR At end of follow-up, % NR Withdrawals due to efficacy, % G1: 0 G2: 3.0 Withdrawals due to adverse events, % G1: 0 G2: NR Very unclear as to when patients discontinued Adherence/ compliance NR
Author, Year Bretlau, 2008^41^ Country, setting Denmark, setting NR, outpatients Funding Commercial source-please list name.supported by Medicon Valley Academy and an unrestricted research grant from H Lundbeck A/S Research Objective To do an interim analysis of a study on active rTMS combined with escitalopram versus sham TMS combined with escitalopram in the acute treatment phase. Quality Rating Fair | Study design RCT Type of analysis Modified ITT (m-itt) N 49 Duration 12 weeks, but primary outcome was at 3 weeks after 15 rTMS sessions completed over a three week period. Escitalopram was adminitered during the entire trial at 20mg daily (10 mg daily for first wk of trial). Primary outcome (HAM-D6) was recorded at baseline, wk 2, 2k 3, 2k 5, 2k 8, and wk 12. Secondary outcome measures (HAM-D17 and MES) were recorded at the same intervals. Interventions B - Repetetive Transcranial Magnetic Stimulation (rTMS)E - Placebo G1: rTMS + escitalopram (n = 25) G2: sham TMS + escitalopram ( n= 24) G1: rTMS + escitalopram G2: sham TMS + escitalopram G1: rTMS + escitalopram** G2: sham TMS + escitalopram** Parameters; - Location = Left Dorslateral prefrontal cortex; - Frequency = 8 Hz; - Intensity = 90% motor threshold; - Per session = 20 trains of 8 seconds at 52-second intervals. Each txt session lasted 20 minutes.; - Number of sessions = 15; Strategy Augment or add-on strategy, for example the patients current treatment of an SSRI was added to or augmented with another treatment | TRD definition Required to be in current episode Yes Setting(s) Not clearly reported Inclusion criteria; - Aged 18 - 75 years;; - meet DSM-IV criteria for current major depressive disorder but not chronic subtype (i.e. current episode not > 24 months);; - failed to respond to at least one previous adequate (at least 6 weeks) antidepressant treatment during the current episode;; - subjects with heart disorders or diabetes were included if they were in a somatically stable phase; Exclusion criteria; - Concurrent diagnosis of an organic brain disorder such as mental retardation, schizophrenia, or other psychotic disorders or personality disorders;; - potential risk factors for escitalopram such as hypersensitivity to the Intervention,; - intake of monoamine-oxidase inhibitors of the irreversible type with the past 14 days,; - pregnancy or insufficient contraception in females of reproductive age;; - risk factors for TMS such as history of epilepsy,; - metal implants in the head or neck regions,; - pacemaker or other electronic implants,; - receiving antipsychotics;; - having major suicide ideation. | Subgroups No sub-group analysis Treatment Failure Failed 1 or more, % G1: 100 G2: 100 Failed 2 or more, % G1: NR G2: NR Current episode failures, mean G1: 2.8 (0.9) G2: 2.5 (0.9) Mean failed trials G1: NR G2: NR Polarity, % Unipolar G1: NR G2: NR Bipolar I G1: NR G2: NR Bipolar II G1: NR G2: NR Patient Characteristics Age, mean yrs G1: 53.1 G2: 57.8 Sex, % females G1: 68% G2: 57% Race, % white G1: NR G2: NR Not Specified, % G1: NR G2: NR Right handed, % G1: NR G2: NR Groups similar at baseline Yes Tier Tier 22A: 1+ failed, MDD | HAM-D Yes HAM-D 17 Other, please describe.HAM-D 6 G1: rTMS + escitalopram G2: sham TMS + escitalopram Baseline n G1: n @ baseline = 25; M-ITT = 23 G2: n@ baseline = 24; M-ITT = 22 Baseline score, mean (SD) G1: HAM-D 17 = 25.3 (3.0); HAM D 6 = 14.0 (1.0) G2: HAM-D 17 = 24.7 (3.2); HAM D 6 = 13.3 (1.5) Endpoint score, mean (SD) G1: HAM-D 17: Awk2 = 19.8 (5.1), Awk3 = 16.4 (4.5), FU wk 5 = 14.5 (5.2), FU wk8 = 12.4 (5.8), FU wk12 = 11.1 (6.7); HAM D 6 = Awk2 = 11.5 (2.6), Awk 3 = 10.0 (2.5), FU wk 5 = 8.9 (2.6), FU wk 8 = 7.9(3.1), FU wk 12 6.7 (4.1) G2: HAM-D 17: = A wk 2 = 22.3(4.5), A wk 3 = 19.1 (4.8), FU wk 5 = 16.3 (5.1), FU wk 8 = 15.3 (6.4), FU wk 12 = 13.5 (7.2); HAM D 6: Awk 2 = 12.5(2.3), A wk 3 = 11.4 (2.7), FU wk 5 = 10.0 (2.9), FU wk 8 = 8.9 (3.6) FU wk 12 = 8.1 (4.2) Change, mean (SD) G1: HAM-D 17 = 14.2 ; HAM D 6 = 7.3 G2: HAM-D 17 = 11.2; HAM D 6 = 5.2 Responders, n G1: NR G2: NR Remitters, n G1: NR G2: NR Other The effect size on the primary outcome measure (HAM-D 6) was greatest after two weeks of therapy (0.80 in favour of rTMS), but after 3 weeks of therapy, the effect size was 0.65 (still > 0.40). It remained above 0.40 at the 12 week endpoint (0.47). HAM-D17 Awk 2 Effect size (95% CI) and Mann-Whitney P = 0.83 (0.22- 1.44), P = 0.02; HAMD17 Awk 3 Effect size (95% CI) and Mann-Whitney P: 0.78 (0.18 - 1.39), P = 0.01; HAM-D17 FU wk 5 Effect size (95% CI) and Mann- Whitney P: 0.48(-0.12 - 1.07), P = 0.09; HAM-D17 FU wk 8 Effect size (95% CI) and Mann-Whitney P: 0.64 (0.04 - 1.24), P = 0.05; HAM-D17 FU wk 12 Effect size (95% CI) and Mann- Whitney P: 0.47 ( - 0.11 - 1.07), P = 0.22; HAM-D6 Awk 2 Effect size (95% CI) and Mann-Whitney P: 0.73 (.018 -1.39), P = 0.05; HAM-D6 Awk 3 Effect size (95% CI) and Mann-Whitney P: 0.80 (0.20 - 1.42), P = 0.01; HAM-D6 FU wk 5 Effect size (95% CI) and Mann-Whitney P: 0.65 (0.09 -1.29), P = 0.02; HAM-D6 FU wk 8 Effect size (95% CI) and Mann-Whitney P:0.50 (-0.10 -1.09), P = 0.10; HAM-D6 FU wk 12 Effect size (95% CI) and Mann-Whitney P: 0.0.50 (-0.10 - 1.09), P = 0.09; BDI G1: rTMS + escitalopram* (See comments) G2: sham TMS + escitalopram Baseline n G1: n @ baseline = 25; M-ITT = 23 G2: n@ baseline = 24; M-ITT = 22 Baseline score, mean (SD) G1: 23.9 (2.4) G2: 23.0 (3.0) Endpoint score, mean (SD) G1: A wk 2 = 19.5 (4.4), A wk 3 = 16.5 (4.7), FU wk 5 = 14.2 (4.7), FU wk 8 = 12.8, FU wk 12 = 11.5 (6.8) G2: A wk 2 = 21.3 (4.1), A wk 3 = 19.2 (4.4), FU wk 5 = 16.4 (5.2), FU wk 8 = 15.4 (6.2), FU wk 12 = 13.6 (6.9) Change, mean (SD) G1: 12.4 G2: 9.4 Responders, n NR Remitters, n NR Other *Bech-Rafaelsen Melancholia scales (MES) reported NOT BDI MES Awk 2 Effect size (95% CI) and Mann-Whitney P = 0.73 (0.12 - 1.33), P = 0.03; Awk 3 Effect size (95% CI) and Mann-Whitney P: 0.84 (0.24 -1.46), P = 0.00; FU wk 5 Effect size (95% CI) and Mann-Whitney P: 0.64(0.02 -1.22), P = 0.03; FU wk 8 Effect size (95% CI) and Mann-Whitney P: 0.65 (0.04 - 1.24 ), P = 0.03; FU wk 12 Effect size (95% CI) and Mann-Whitney P: 0.46 ( -0.12 - 1.06), P = 0.12; MADRS NR IDS NR CGI-S NR CGI-I NR Instrument Major Depression Inventory (MDI) Baseline n G1: n @ baseline = 25; M-ITT = 23 G2: n@ baseline = 24; M-ITT = 22 Baseline score, mean (SD) G1: 33.5 (5.1) G2: 34.0 (5.6) Endpoint score, mean (SD) G1: A wk 2 = 23.8 (9.0), A wk 3 = 21.5 (9.8), FU wk 5 = 20.1 (9.0), FU wk 8 = 18.4 (10.0), FU wk 12 = 16.1 (10.7) G2: A wk 2 = 27.9 (10.6), A wk 3 = 26.6 (9.9), FU wk 5 = 23.7 (9.5), FU wk 8 = 21.5 (11.0), FU wk 12 = 19.6 (12.8) Change, mean (SD) G1: 17.4 G2: 14.4 MDI Awk 2 Effect size (95% CI) and Mann-Whitney P = 0.36 (-0.23 - 0.94), P = 0.18; Awk 3 Effect size (95% CI) and Mann-Whitney P:0.43 (-0.16 - 1.03), P = 0.29; FU wk 5 Effect size (95% CI) and Mann-Whitney P: 0.29 (-0.29 - 0.88), P =0.20; FU wk 8 Effect size (95% CI) and Mann-Whitney P: 0.22 (-0.36 - 0.81 ), P = 0.72; FU wk 12 Effect size (95% CI) and Mann-Whitney P: 0.23 ( -0.36 -0.81), P = 0.43; | Quality of Life NR Adverse Events Overall NR Amnesia, % G1: memory impairment: 3wk/ 12 wk mean: 0.00/0.00 G2: 0.13/0.00 Cardiovascular adverse events, % G1: palpatations: 3wk/12 wk mean: 0.23/0.14 G2: 0.30/0.12 Cognitive impairment, % G1: concentration difficulties 3wk/ 12 wk mean: 1.43/0.71 G2: 1.52/1.22 Headache, % G1: 3wk/ 12 wk mean: 0.18/0.10 G2: 0.43/0.06 Insomnia, % G1: reduced duration of sleep 3wk/ 12 wk mean: 0.45/0.24 G2: 0.91/0.39 Somnolence, % NR Suicidality, % NR Additional Comments **Adverse events are reported by the UKU side-effect scale and reported as mean and standard deviation** Sig differences (P <= 0.05) compared to active: at 3wks, with sham pts have higher reduction in sleep; at 12 wks, more sham pts have concentration difficulties Study utilized the UKU scale as listed before - Other adverse events inlcude: tension/inner unrest: Sham AK wk 3 = 1.48 (0.67)/ FU wk 12 = 0.89 (0.32); rTMS A wk 3 = 1.36 (0.49), FU wk 12 1.00 (0.63); Tremor: Sham AK wk 3 = 0.17 (0.39)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.14 (0.35), FU wk 12 0.05 (0.12); Akathisia: Sham AK wk 3 = 0.04 (0.21)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.05 (0.21), FU wk 12 0.00 (0.00); Nausea: Sham AK wk 3 = 0.35 (0.49)/ FU wk 12 =0.17 (0.51); rTMS A wk 3 = 0.14 (0.35), FU wk 12 0.05 (0.22); Diarrhea: Sham AK wk 3 = 0.09 (0.29)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.14 (0.35), FU wk 12 0.10 (0.30); Diminished Sexual Desire: Sham AK wk 3 = 1.45 (0.74)/ FU wk 12 =0.94 (0.73); rTMS A wk 3 = 1.27 (0.94), FU wk 12 0.71(0.56); Dry Mouth: Sham AK wk 3 = 0.43 (0.56)/ FU wk 12 = 0.11 (0.32); rTMS A wk 3 = 0.27 (0.46), FU wk 12 0.14(0.36); Micturia: Sham AK wk 3 = 0.09 (0.29)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.05 (0.22), FU wk 12 0.00 (0.00); Neuropsychological or executive functioning No Measures, Results NR Predefined Yes MMSE No NR Baseline n NR Baseline score, mean (SD) NR Endpoint score, mean (SD) NR Change, mean (SD) NR Other Other Yes Study utilized the UKU scale as listed before - Other adverse events inlcude: tension/inner unrest: Sham AK wk 3 = 1.48 (0.67)/ FU wk 12 = 0.89 (0.32); rTMS A wk 3 = 1.36 (0.49), FU wk 12 1.00 (0.63); Tremor: Sham AK wk 3 = 0.17 (0.39)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.14 (0.35), FU wk 12 0.05 (0.12); Akathisia: Sham AK wk 3 = 0.04 (0.21)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.05 (0.21), FU wk 12 0.00 (0.00); Nausea: Sham AK wk 3 = 0.35 (0.49)/ FU wk 12 =0.17 (0.51); rTMS A wk 3 = 0.14 (0.35), FU wk 12 0.05 (0.22); Diarrhea: Sham AK wk 3 = 0.09 (0.29)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.14 (0.35), FU wk 12 0.10 (0.30); Diminished Sexual Desire: Sham AK wk 3 = 1.45 (0.74)/ FU wk 12 =0.94 (0.73); rTMS A wk 3 = 1.27 (0.94), FU wk 12 0.71(0.56); Dry Mouth: Sham AK wk 3 = 0.43 (0.56)/ FU wk 12 = 0.11 (0.32); rTMS A wk 3 = 0.27 (0.46), FU wk 12 0.14(0.36); Micturia: Sham AK wk 3 = 0.09 (0.29)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.05 (0.22), FU wk 12 0.00 (0.00); Adequate information Yes Attrition Overall, % 3 RTMS patients did not complete protocol, and 1 sham patient did not complete (analysis used last observation carried forward). At 3 week outcome, all 45 patients in m-ITT were present. By end of study at 12 weeks, 6/49 (12%) had dropped out. At end of treatment, % G1: At end of rTMS (3 wks) = 0 G2: At end of Sham (3 wks) = 0 At end of follow-up, % G1: 21% G2: 4% Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR Adherence/ compliance NR

Evidence Table 18 KQ 4. Adverse Events : Tier 1 (VNS vs. sham—MDD/Bipolar)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Rush et al., 2005^24^, Country, setting US, multicenter, outpatient psychiatric Funding Cyberonics, Inc. Research Objective To compare adjunctive VNS to sham in TRD patients Quality Rating Fair | Study design RCT Type of analysis m-ITT/PP for efficacy, ITT for Aes N 235 Duration 10wks of stimulation Primary Outcome: HAM- D Response after 10wks txt Interventions G1: VNS G2: Sham Medications allowed pts allowed up to 5 antidepressants, mood stablizers, or other psychotropic medications Strategy Augmentation Parameters VNS: Frequency (Hz): 20 Pulse width (seconds): 500 μs; - On/Off cycle parameters: 30 sec on and 5 min off; Sham:; - Device implanted but not turned on | TRD definition; - TRD (2-6 failures verified by the ATHF, with failures in tw different drug classes); - Required to be in current episode; Tier 1 Inclusion criteria; - Current Major Depressive Episode (MDE) of 2+ yrs OR 4+ MDE in lifetime,; - age 18-80, HAM-D24>=20;; - bipolar pts had to also be resistant, intolerant of, or have contraindications to lithium; Exclusion criteria; - Atypical or psychotic features in any MDE; - current rapid cycling bipolar disorder, delerium, dementia, amnesia; - other cognitive disoder, suicidality; - risks related to surgical implantation | Treatment Failure Percent with 4-6 current episode failures G1: 46.5% G2: 40.0% Polarity, % Unipolar G1: 88.4 G2: 90.9 Bipolar I G1: 5.4 G2: 3.6 Bipolar II G1: 6.3 G2: 5.5 Age, mean yrs G1: 47.0 G2: 45.9 Sex, % females G1: 59 G2: 66 Race, % white G1: 97 G2: 96 HAM-D24 Baseline n G1: 119 G2: 116 Baseline score, mean (SD) G1: 28.8(5.3) G2: 29.7(5.2) MADRS Baseline score, mean (SD) G1: 31.4(6.3) G2: 31.9(6.3) IDS Baseline n G1: 112 (115 randomized) G2: 110 Baseline score, mean (SD) G1: 44.3(9.1) G2: 45.4(8.5) CGI-I Baseline n G1: 112 G2: 110 | HAM-D24 N analyzed G1: 112 G2: 110 Endpoint score, mean (SD) NR % change, mean (SD) G1: -16.3 (28.1) G2: -15.3 (25.5) P = 0.639 Responders, n G1: 17 (15.2%) G2: 11 (10.0%) P = 0.251 MADRS Endpoint score, mean (SD) NR % change, mean (SD) G1: -17.1 (31.2) G2: -12.4 (27.1) P = 0.208 Responders, n G1: 17 (15.2) G2: 12 (0.0) P = 0.378 IDS Endpoint score, mean (SD) NR % change, mean (SD) G1: 21.2 (25.4) G2: 16.3 (26.2) P = 0.158 Responders, n G1: 19 (17) G2: 8 (7.3) P = 0.032 Remitters, n NR CGI-I Endpoint score, mean (SD) NR Achieving 1 or 2 score, %(SD) G1: 13.9 G2: 11.8 VNS v. Sham, P = 0.648 | Quality of Life Medical Outcomes Study Short Form-36 (MOS-SF36) Baseline n G1: 112/ N=107 QOL analysis G2: 110/ N=107 QOL analysis Baseline score, mean (SD) NR Endpoint score, mean (SD) NR Change, mean (SD) G1: physical component: -0.9 (8.3); mental component: 5.0 (11.6) G2: physical component -1.6(8.4); mental component: 4.0(10.2) Other Physical component between VNS and sham: P = 0.480, Mental Component between VNS and sham: P = 0.406 Adverse Events Overall, % NR Cardiovascular adverse events, % G1: 5, palpitations 5 G2: 3 Other:–; - voice alteration: 68% v 38%; - cough increased: 29% v 9%; - dyspnea: 23% v 14%,; - dysphagia: 21% v 11%,; - neck pain: 21% v 10%,; - paresthesia: 16% v 10%,; - vomiting: 11% vs. 12%,; - laryngismus 11% v 2%,; - dyspepsia 10 v 5; - wound infection 8% v 2%,; - hypomania/mania (via Young Mania Scale): 1.7% (1pt with a prestudy dx of bipolar) v 0%; Overall SAEs 30, pts VNS: 13.4% (16/119). Sham: 12.1% (14/116) 12 events, involving 11 patients, were cases of worsening depression requiring hospitalization Cardiac SAEs during implantation: 1.7% v 0% COSTART used to code reported events Attrition Overall, % 1.3 (3/235) At end of treatment, % G1: 2.6 G2: 0 At end of follow-up, % NR Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % G1: 2.6 G2: 0 9 pts had a protocol violation post randomization Adherence/ compliance NR

Evidence Table 19 KQ 4. Adverse Events : Tier 2 (rTMS vs. sham—MDD/Bipolar)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Berman et al., 2000^28^ Country, setting US, urban community health center, inpatient and outpatients Funding Veterans Administration, NIMH, State of CT Research Objective To assessefficacy of rTMS in unmedicated TRD patients Quality Rating Fair | Study design RCT Type of analysis ITT N 20 Duration 2 weeks (10 weekdays of txt) Primary outcome = HAM-D at 2wks Interventions G1: rTMS G2: Sham TMS Medications Allowed All patients free of antidepressants, neuroleptics, and benzodiazepines Inpatients pts allowed chloral hydrate for sleep Strategy Switch Parameters rTMS –; - Frequency (Hz): 20; - Motor threshold (%): 80; - Number of trains: 20; - Length of train (seconds): 2; - Inter-train interval:58; - Pulses per session:800; - Total number of sessions: 10 in 10 days; Sham; - Paddle angled approximately 30 – 45 degrees off of scalp with bottom coil margin elevated approximately one-half cm from scalp and lucite paddle casing firmly applied against the scalp | TRD definition; - 1+ failed trials (4+ weeks duration with at least 200 mg mg/d of imiprimine, 20mg/day fluoxetine, 60mg/d phenelzine, 225mg/d venlafaxine, 30mg/d mirtazapine); - Not required to be in current episode; Tier 2 Inclusion criteria; - Current Major depressive episode (via Ham-D); Exclusion criteria; - Hx of sig. neurological illness; - EEG abnormalities suggestive of an epileptic predisposition; - Substance or alcohol use abuse diagnosis,; - Sig. unstable medical illness,; - Females - pregnancy or inadequate birth control | Treatment Failure Current episode failures, mean G1: 5 G2: 3.5 (+ a median of 1 aumgmentation in eachgroup) Polarity, % Unipolar G1: 100 G2: 90 Bipolar II G1: 0 G2: 10 Age, mean yrs G1: 45.2 G2: 39.4 Sex, % females G1: 20 G2: 40 Race, % white G1: 100 (n=1 hispanic) G2: 100 (n=1 hispanic) HAM-D 25 Baseline n G1: 10 G2: 10 Baseline score, mean (SD) G1: 37.1 G2: 37.3 | HAM-D 25 G1: rTMS G2: Sham TMS Endpoint score, mean (SD) At week 2 G1: 24.6 G2: 36.4 *Adjusted Change (based on best fit slopes), mean (SEM) G1: -14.0 (3.7) G2: -0.2 (4.1) P < 0.05 Responders, n 50% decrease from baseline and score <= 15 G1: 1 (10) G2: 0 P = 0.09 Three partial responders symptom severity returned to baseline within 1-2 weeks BDI Change, mean (SD) G1: 11.4 (5) G2: 4.7 (6) P = 0.27 | Quality of Life NR Adverse Events Headache, n G1: 60 G2: 50 Difficulty starting urination great in active group P = 0.03 Remaining 21 potential side effects assessed by the SECL were not significantly different between groups after correction for multiple comparisons (data NR); - Poor memory, nausea or vomiting, constipation, drowsiness, blurred vision, increased appetite, dry mouth, decreased appétit, tremors and shakiness, nightmares, difficulty sitting still, trouble concentrating, irregular or pounding heartbeat, diarrhea, frequent need to urinate, rash, ringing in the ears, sweating, faintness or lightheadedness, poor coordination, and muscle stiffness; MMSE NR Attrition Overall, % 15 At end of treatment, % G1: 0.0 G2: 30.0 At end of follow-up, % G1: NA G2: NA Withdrawals due to efficacy, % G1: 0 G2: 30 Withdrawals due to adverse events, % G1: 0 G2: 0 Adherence/ compliance NR

Evidence Table 20 KQ 4. Adverse Events: Tier 3 (ECT vs. rTMS—MDD/Bipolar)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year McLoughlin et al., 2007^7^ Eranti et al., 2007^8^ Knapp et al., 2008^9^ Country, setting UK, South London and Maudsley NHS Trust and Pembury Hospital inInvicta Mental Health Trust in Kent, 65.2% were inpatients Funding National Health Service Research and Development, National Coordinating Centre for Health Technology Assessment (NCCHTA) (98/11/04); byGuy's and St. Thomas's Charitable Foundation (R001126); and by a 2003 Ritter Independent Investigator Award from National Alliance for Research on Schizophrenia and Depression. Research Objective To assess clinical effectiveness of rTMS vs. ECT for treating major depressive episodes in patients referred for ECT Quality Rating Good | Study design RCT- pragmatic and single blinded (raters) Type of analysis m-ITT N 46 Duration Primary endpoint at 3 weeks for rTMS and at clinicians discretion for ECT, additional follow-up at 6 months Interventions G1: ECT G2: rTMS Medication Allowed Patients continued their usual medical care and stable psychotropic medications were allowed (i.e. SSRIS, TCAs, Venlafaxine, Mirtazapine, Lithium, Anticonvulsant mood stabilizers, Benzodiazepines, Antipsychotics, Zopiclone, L-Tryptophan) Strategy Augmentation Parameters rTMS; - Frequency (Hz): 10; - Motor threshold (%):110; - Number of trains: 20; - Length of train (seconds): 5; - Inter-train interval: 55; - Pulses per session: 1000; - Total number of sessions:15; ECT:; - % receiving bilateral: 82; - Intensity: 1.5 × ST for bilateral frontotemporal ECT and 2.5 × ST for right unilateral ECT; - Number of sessions (range, mean, SD): range = 2-10, mean = 6.3, SD = 2.5 | TRD definition; - All patients referred for ECT:; - No failure required; Tier 3 Inclusion criteria; - Right handed patients; - more than 18 years old; - refered for ECT due to major depressive episode; Exclusion criteria; - Inability to have rTMS because of metallic implants or foreign bodies; - History of seizures; - Substance misuse in previous 6 months; - Being medically unfit for general anesthesia or ECT:; - ECT or rTMS in previous 6 months,; - Dementia or other axis I diagnosis; - Inability or refusal to provide informed consent. | Treatment Failure Mean failed trials G1: 2.5 (1.4) G2: 2.4 (1.0) Polarity, % MDD G1: 91.67 G2: 90.91 Bipolar G1: 8.33% G2: 9.09 % Age, mean yrs G1: 63.6 G2: 68.3 Sex, % females G1: 67.7 G2: 72.7 Right handed, % Overall: 100% HAM-D 17 Baseline n G1: 22 G2: 24 Baseline score, mean (SD) G1: 24.8 (5.0) G2: 23.9 (7.0) BDI: Baseline score, mean (SD) G1: 36 (8.7) G2: 37.8 (10.5) | HAM-D 17 Analyzed n G1: 22 G2: 23 Endpoint score, mean (SD) End of treatment G1: 10.7 G2: 18.5 P = 0.002, effect size of 1.44 Follow-up at 6 months G1: NR G2: NR P = 0.93 Change, mean (SD) End of treatment G1: -14.1 G2: -5.4 P = 0.017 Responders, n End of treatment G1: 13 (59.1%) G2: 4 (17.4%) P = 0.005 Remitters, n HAM-D ≤ 8 End ot treatment G1: 13 (59.1%) G2: 4 (17.4%) P = 0.005 Follow-up at 6 months* G1: 6 (27.4%) G2: 2 (8.7%) *only 12 ECT remitters followed after End of txt BDI Endpoint score, mean (SD) NR P = 0.01 effect size=0.9 Change, mean (SD) NR Group × time, P = 0.25 Responders, n NR Remitters, n NR | Quality of Life SF-36 mental health component score Baseline n G1: 24 G2: 22 Baseline score, mean (SD) G1: 48.9 (12.6) G2: 42.7 (7.5) Other: QALYs Six month QALY gain, mean (SD) G1: 0.0300 (0.053) G2: 0.0297 (0.056) (QALYs were derived using SF-36 data). At six month follow-up, service use data were collected on 28 pts (10-ECT and 18-rTMS). Patients responded much better to ECT than to rTMS by the end of the allocated treatment course. The differential QALY gain of treatment with rTMS over ECT was 0.0003 (p = 0.987). This suggests that treatment by rTMS does not provide any additional gains in quality of life over ECT over a 6-month period. The lack of a statistically significant difference in QALY gain between the two groups may reflect lack of difference in HRSD scores between groups at 6 months. Adverse Events NR Neuropsychological or executive functioning Predefined CAMCOG Attention and orientation subscale (max = 17): ECT baseline 12.8 (3.2), end of treatment 13.9 (3.6), 6mos 13.9 (3.5) rTMS baseline 14.7 (3.0) end of treatment 13.5 (3.3) FU6mos 13.4 (3.8), P = 0.004 No significant differences for rest of CAMCOG subscales (verbal fluency, anterograde memory, and retrograde memory) MMSE Baseline score, mean (SD) G1: 24.3 (3.6) G2: 25.7 (3.9) Score at 6 months, mean (SD) G1: 25.4 (5.3) G2: 24.7 (4.8) Endpoint score, mean (SD) G1: 25.6 (3.9) G2: 24.4 (5.3) Change, mean (SD) G1: 1.3 G2: -1.3 P < 0.08 No significant differences on the Columbia ECT Subjective Side Effects Schedule for self-reported cognitive side effects. Attrition Overall to end of treatment 6/46, at 6 months 9/46 At end of treatment, % G1: 6/24 G2: 0 At end of follow-up, % NR Withdrawals due to efficacy, % G1: 5/24 G2: 0 Withdrawals due to adverse events, % 0 Adherence/ compliance NR
Author, Year O'Connor, 2003^64^ Country, setting United States, University Hospital, inpatient vs. outpatient population not clearly reported Funding NIH/NIMH and a NARSAD grant Research Objective Two procedures for treating major depressive disorder were compared with regard to their respective effects on mood and cognition Quality Rating Poor | Study design Observational Type of analysis Completers N 28 Duration; - Primary outcome at end of treatment (ECT applied for 2 to 4 weeks and rTMS a period of 2 weeks).; - Patients assessed for follow-up 2 weeks post txt; Medications allowed rTMS patients completed a washout of all psychotropic medications while ECT continued all medications Strategy Switch strategy for rTMS and augment or add-on strategy for ECT group Interventions G1: ECT G2: rTMS Parameters ECT; - % receiving bilateral:0; - Intensity: 2.5 times seizure threshold; - Number of sessions (range, mean, SD): 6-12; rTMS; - Frequency (Hz):10; - Motor threshold (%): 90; - Number of trains: 20; - Length of train (seconds): 8; - Inter-train interval: 24; - Pulses per session: 1600; - Total number of sessions:5/wk over 2wks | TRD definition; - Patients referred for ECT; - AD failures not required; Tier 3 Inclusion criteria; - Met criteria for MDD; - HRSD > 18; Exclusion criteria; - Psychosis, acute suicidality, other current Axis I diagnoses in DSM IV; - known CNS pathology, pacemakers, electronic or metallic implants, severe cardiac pathology; - personal or first degree family history of a seizure disorder; - inability to give informed consent | Treatment Failure Mean failed trials NR Polarity, % 100% MDD Age, mean yrs G1: 48.4+/- 12.0 G2: 51.2 +/- 12.2 HAM-D Baseline n Completers G1: 14 G2: 14 Baseline score, mean (SD) G1: 38.07 (8.1) G2: 29.3 (4.9) P = 0.001 Wechsler Memory Scale-III (WMS-III)-Letter Number Sequencing subtest Baseline n G1: 14 G2: 14 Baseline score, mean (SD) G1: 10.92 (2.49) G2: 10.42 (3.0) | HAM-D Endpoint score, mean (SD) End of treatment G1: 15.3 (11.7) G2: 25.6 (7.7) Follow-up 2 weeks G1: 20.4 (9.5) G2: 24.8 (9.5) Change, mean (SD) End of treatment G1: -23.7 G2: -3.73 Group × time P < 0.01 Responders, n G1: NR G2: 0 Remitters, n G1: NR G2: 100% Other Validated measure Yes Wechsler Memory Scale-III (WMS-III)-Letter Number Sequencing subtest Endpoint score, mean (SD) G1: 9.23 (1.83) G2: 10.71 (3.83) Change, mean (SD) At two weeks ECT scores on LN based on completers per protocol (n=13). ECT pts did not demonstrate a significant change in LN performance compared directly with2 week follow-up results (P > 0.05) No significant interaction between treatment sessions and groups with respect to LN (P > 0.05) | Quality of Life Adverse Events NR Neuropsychological or executive functioning Rey Auditory Verbal Learning Test-RAVLT (15 item word list to test new learning) Baseline n G1: 14 G2: 14 Baseline score, mean (SD) G1: 43.78 (11.07) G2: 43.71 (12.09) Endpoint score, mean (SD) G1: 29.14 (7.93) G2: 43.00 (10.00) Change, mean (SD) G1: 46.92 (10.80)/Difference between baseline acquisition and performance on acquisition task during 2-wk f/u session was not significant: P > 0.05 G2: 44.07 (10.43) RAVLT, Acquisition, mean (SD) Baseline: ECT 43.78 (11.07) vs. rTMS 43.71 (12.09). End of treatment: ECT 29.14 (7.93) vs. rTMS 43.00 (10.09) P < 0.01. Two weeks later: ECT 46.92 (10.80) vs. rTMS 44.07 (10.43) P > 0.05. RAVLT, Retention,(15-item word list after a 20-minute delay interval), mean (SD) Baseline ECT 8.07 (4.49) words vs. rTMS 9.76 (3.08) End of treatment ECT 2.14 ( 1.99) vs. rTMS 8.23 (2.80) Two weeks later, ECT 8.92 (4.14) vs. rTMS 8.31 (4.07). Transient News Events Test (TNET-measure of retrograde memory) Baseline n G1: 14 G2: 14 Baseline score, mean (SD) G1: 64.30 (19.40) G2: 55.62 (18.12) Endpoint score, mean (SD) G1: 39.10 (13,.21) G2: 57.81 (18.33) Change, mean (SD) G1: 59.20 (20.67) G2: 61.54 (19.12) Other Main-effect-of-group (P > 0.05). There was evidence of a significant interaction b/t txt grp and txt session: P < 0.001. Cognitive function/memory impairment reported as primary outcome measures. MMSE NR Attrition Overall, % No attrition At end of treatment, % NR At end of follow-up, % NR Withdrawals due to efficacy, % 0 Withdrawals due to adverse events, % 0 Adherence/ compliance NR

Evidence Table 21 KQ 4. General Tolerability: Tier 1 (ECT vs . rTMS—MDD only)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Schulze-Rauschenbach et al., 2005^63^ Country, setting Germany, Psychiatric University Hospital, inpatients Funding NR Research Objective To compare neurocognitive effects of unilateral ECT and rTMS using a control Quality Rating Fair | Study design Observational Type of analysis Observational study of patients completing txt N 30 Duration Not clear- testing took place 8.8 days on average after last treatment Estimated duration from mean number of txt – ECT 5 weeks and rTMS 3-5 weeks. Interventions Control G1: ECT G2: rTMS Medications Allowed Antidepressants, low-potency neuroleptics and non-benzodiazepine hypnotics were allowed in both groups. No med changes allowed during study Parameters ECT:; - % receiving bilateral: 0; - Intensity: 2.0-2.5 times seizure threshold; - Number of sessions (range, mean, SD): 9.9 (2.7); rTMS; - Frequency (Hz): 10; - Motor threshold (%): 100; - Number of trains: 20-30; - Length of train (seconds): 2; - Inter-train interval: 5; - Pulses per session:; - Total number of sessions: 2-3/wk; Strategy Augment or add-on | TRD definition; - Unsuccessful treatment response to at least two different types of antidepressants, each given in a sufficient dosage range for at least 4 weeks; - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - Consecutively admitted patients with DSM–IV diagnosis of MDD; - Age over 18 years; Exclusion criteria; - Previous treatment with ECT or rTMS; - Additional Axis I diagnosis | Treatment Failure Mean failed trials NR Polarity, % Unipolar 100% MDD Age, mean yrs G1: 46.7 G2: 47.7 Sex, % females G1: 50 G2: 44 HAM-D 17 Baseline n G1: 14 G2: 16 Baseline score, mean (SD) G1: 22.4 (3.1) G2: 21.3 (3.5) BDI Baseline n G1: 14 G2: 16 SSMQ Baseline n G1: 14 G2: 16 Baseline score, mean (SD) G1: -20.7 (19.0) G2: -16.8 (16.9) | HAM-D 17 Endpoint score, mean (SD) G1: 14.5 (5.7) G2: 13.0 (4.9) Change, mean (SD) G1: -7.9 G2: -8.3 Group × time, P = NS Responders, n G1: 6 (46%) G2: 7 (44%) P = 0.90 BDI Change, mean (SD) G1: 7.6 G2: 6.4Group × time, P = NS SSMQ Endpoint score, mean (SD) G1: -15.2 (25.2) G2: 3.8 (11.8) Change, mean (SD) G1: 5.5 G2: 20.6 | Quality of Life NR Adverse Events One patient in ECT group withdrew due to severe orientation and memory problems following two treatments; data not included. Neuropsychological or executive functioning Test scores ECT Pre / Post vs. rTMS Pre / Post Post; P = Post Ect vs. Post rTMS Learning and anterograde memory AVLT Immediate recall (trials 1-5); P = NS Recall after interference (trial 5 minus trial 6) 2.8 (2.2) / 3.9 (1.9) vs. 3.2 (1.9) / 1.8 (2.0); P < 0.01 Recall after delay (trial 5 minus trial 7) 2.4 (1.8) / 4.2 (1.6) vs. 3.2 (1.6) / 2.4 (2.0); P < 0.05 Recognition hits; P = NS and false alarms; P = NS MPT Recall trial; P = NS and Delayed recall; P = NS Retrograde memory Retrograde AVLT Recall; P = NS and Recognition hits; P = NS Recognition false alarms 5.0 (3.0) vs. 1.1 (1.1); P < 0.05 Four-card task Free recall 2.0 (1.4) / 0.4 (0.5) vs. 1.4 / (1.2); P < 0.05 Recognition; P = NS AMI Recall score; P = NS Subjective memory SSMQ -20.7 (19.0) / - 15.2 (25.2) vs. -16.8 (16.9) / 3.8 (11.8); P < 0.05 Other cognitive functions MMSE; P = NS, TrailMakingTest A; P = NS, TrailMakingTest B; P = NS, Digit span (WAIS-R); P = NS, Letter-number span; P = NS, Word fluency (LPS); P = NS MMSE G1: ECT G2: rTMS Recognition G3: Control Baseline n G1: 14 G2: 16 G3: 15 Baseline score, mean (SD) G1: 27.9 (1.7) G2: 26.9 (3.4) G3: 29.1 (1.0) Endpoint score, mean (SD) G1: 28.3 (1.3) G2: 27.9 (3.0) G3: 29.2 (1.1) Change, mean (SD) G1: 0.4 G2: -1 G3: 0.01 Other P = NS Attrition Overall, % 3.3 At end of treatment, % G1: 7 G2: 0 At end of follow-up, % G1: NR G2: NR Withdrawals due to efficacy, % G1: 0 G2: 0 Withdrawals due to adverse events, % G1: 7 G2: 0 One person in ECT group withdrew because of severe orientation and memory problems after 2 ECT treatments; these data were not included inanalysis Adherence/ compliance NR

Evidence Table 22 KQ 4. General Tolerability: Tier 1 (rTMS vs. sham—MDD only)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Avery et al., 2006^10^ Country, setting USA, Single center, University, Department of Psychiatry, outpatient Funding NIMH Research Objective To test hypothesis that patients receiving active TMS would show a greater antidepressant response rate than those receiving sham stimulation Quality Rating Good Fair for KQ2 and subgroups11 (small number of people followed for relapse; used a single measure and did not account for additional medical conditions) | Study design RCT Type of analysis ITT N 68 Duration 4 weeks (15 sessions) of txt, primary assessment 1 week after completion of txts. Responders were evaluated for relapse 2 wks after primary endpoint Interventions G1: High-left TMS G2: Sham Medications Allowed; - Pts encouraged, although not required, to discontinue current antidepressant medication, sedatives, or benzodiazepines; (continuing AD medication G1: 31% vs. G2: 27%; continuing benzodiazapines G1: 26% vs. G2: 24%); - Those stopping medications had to be medication-free for at least 2 weeks; - All responders given AD post rTMS treatment (active or sham); Strategy Mixed-within group differences Parameters rTMS; - Frequency (Hz):10; - Motor threshold (%): 110; - Number of trains: 32; - Length of train (seconds): 5; - Inter-train interval: 25- 30; - Pulses per session: 1600; - Total number of sessions: 15 in 4 wks; Sham; - Identical stimulation parameters; - Lateral edgeof coil rotated 90° away from scalp | TRD definition; - Failed to respond to or unable to tolerate at least 2+ adequate AD trials (defined by score ≥3 on ATHF); - Failures not required to be in current episode; Tier 1 Inclusion criteria; - TRD; - 21 to 65 years old; - DSM-IV criteria for current major depressive disorder (MDD); - HAM-D 17 ≥ 17 and a decrease of no more than 20% between screening and 1st txt day; Exclusion criteria; - Previous TMS exposure; - bipolar disorder,; - previous failure of nine or more bitemporal ECT treatments; - current major depressive episode longer than 5 years; - history of substance abuse or dependence; Within past 2 years,; - antisocial or borderline personality disorder,; - active suicidal ideation; - current symptoms of psychosis,; - Hx of seizure disorder,; - Hx of closed head injury with loss of consciousness or prior brain surgery; - any other major psychiatric or medical comorbidity | Subgroups Pain, subgroup analysis presented in Avery et al, 2007^11^ Baseline n G1: 35 G2: 33 Treatment Failure Current episode failures, mean (SD) G1: 1.46 (0.78) G2: 1.48 (0.67) Mean failed trials (SD) G1: 3.2 (2.44) G2: 3.3 (1.72) Polarity, % Unipolar 100 Age, mean yrs G1: 44.3 G2: 44.2 Sex, % females G1: 60 G2: 52 Race, % white NR Right handed, % NR Groups similar at baseline Yes HAM-D 17 Baseline score, mean (SD) G1: 23.5 (3.9) G2: 23.5 (2.9) BDI Baseline score, mean (SD) G1: 28.1 (8.7) G2: 28.4 (8.0) | HAM-D 17 Endpoint score, mean (SD) G1: 15.7 G2: 19.8 Change, mean (SD) G1: -7.8 (7.8) G2: -3.7 (6.3) Group × time P = 0.002 Responders, n G1: 11 (31.4%) G2: 2 (6.1%) P = 0.008 Remitters, n HAM-D21 < 10 G1: 7 (20.0%) G2: 1 (3.0%) P = 0.033 No Relapse (at 6mos), N G1: 5 G2: Unknown (1 relapsed, 1 loss to follow after 3 mos of without relapse) BDI Change, mean (SD) G1: 11.3 (12.8) G2: 4.8 (8.5) Random Regression analyses revealed significant group by time interaction (P = 0.003) | Quality of Life NR Adverse Events Overall, % NR Site pain first session sham none (0/33) vs. TMS group, 41% (14/35)15th session sham 3% (1/30) vs. TMS 33% (11/33). The discomfort pain scale ratings (0-4) decreased inTMS group in subsequent treatment sessions, decreasing from a mean of 1.89 ( 1.02) at session 1 to 1.11 ( 1.03) at session 15 (t = 4.24, P < 0.001). Changes from baseline in128 individual SAFTEE scores -emerging symptoms were analyzed by chi-square analyses at visits 5, 10, 15, and 16 with a Bonferroni correction, there were no significant differences between TMS and sham in any ofemerging symptoms. (Data = NR) Neuropsychological or executive functioning No sig differences in GOAT, RAVLT, WAIS-R, COWAT, and SAFTEE; SUBGROUP ANALYSIS^11^: At 15th session pain TMS 33% vs, sham 3% (P < 0.05) no statistically significant (P > 0.05) time by treatment group interactions for any of neuropsychological test measures.,There was significant improvement in individual neuropsychological test performances for both groups. No confusion was associated withTMS treatments.GOAT assessments were well within normal range and ranged from 98 to 100. No significant (P > 0.05) differences between groups for any session. MMSE NR Attrition Overall, % 7.4% (5/68) At end of treatment, % NR At end of follow-up, % NR Withdrawals due to efficacy,% G1: 0 G2: 3.0 Withdrawals due to adverse events, % G1: 0 G2: NR Very unclear as to when patients discontinued Adherence/ compliance NR
Author, Year Garcia-Toro et al., 2006^17^ Country, setting Spain, single center, all outpatients Funding Fundacio La Marato de TV3 Research Objective To assess the efficacy of high and low frequency rTMS and different locations of activation Quality Rating Fair | Study design RCT Type of analysis Cannot tell, all reported patients included in analysis N 30 Duration; - Primary outcome after 2 weeks of active treatment; - Follow-up: 2 weeks post treatment; Interventions G1: Sham G2: rTMS G3: rTMS + SPECT (focused on different regions of brain after examination with single photon emission computed tomography [SPECT] exam) Medications allowed All pts continued (failed) AD medication and other psychotropic meds Strategy Augmentation Parameters rTMS Low:; - Frequency (Hz):1; - Motor threshold (%): 110; - Number of trains: 30; - Length of train (seconds): 60; - Inter-train interval:; - Pulses per session: 1800; - Total number of sessions: 10 in 2 wks; High; - Frequency (Hz):20; - Motor threshold (%): 110; - Number of trains: 30; - Length of train (seconds): 2; - Inter-train interval: 20+5; - Pulses per session: 1200; - Total number of sessions: 10 in 2 wks; Sham; - Same but with coil angling 45 degrees away from scalp | TRD definition; - Failed 2+ txt trials at 4+ weeks; - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - At least 18 yrs old, MDD, unipolar; Exclusion criteria; - Contraindications for rTMS and high suicide risk | Subgroups None Treatment Failure Mean failed trials NR Polarity, % Unipolar 100% Age, mean yrs G1: 47.2 G2: 48.5 G3: 51.1 Sex, % females G1: 70 G2: 40 G3: 40 Race, % white NR Right handed, % G1: 90% G2: 100% G3: 100% HAM-D 21 Baseline n G1: 10 G2: 10 G3: 10 Baseline score, mean (SD) G1: 25.10 (7.28) G2: 27.30 (4.97) G3: 25.00 (4.14) CGI-S Baseline n G1: 10 G2: 10 G3: 10 Baseline score, mean (SD) G1: 4.7 (0.82) G2: 4.8 (1.0) G3: 4.8 (0.63) | HAM-D 21 Endpoint score, mean (SD) At week 1 G1: 23.6 (7.04) G2: 24.1 (7.91) G3: 21.6 (3.10) At week 2 G1: 23.6 (7.79) G2: 20.10 (8.18) G3: 18.10 (6.15) Follow-up 2 weeks post treatment G1: 23.67 (5.55) G2: 20.88 (7.26) G3: 16.9 (7.0) Change, mean (% change) At 1 week G1: -1.5 (-5.9%) G2: -3.2 (-13.27%) G3: -3.4 (-13.6%) At 2 weeks G1: -1.5 (-5.9%) G2: -7.2 (-26.37%) G3: -6.9 (-27.6%) G1: vs. G2+G3 (mean = 7.05), P = 0.048 Follow-up at week 4 G1: -1.43 (-5.6%) G2: -6.42 (-23.51%) G3: -8.1 (-32.4%) G1: vs. G2+G3, P = 0.121 Responders, n (%) G1: 0 (0) G2: 2 (20) G3: 2 (20) P = NR CGI-S Endpoint score, mean (SD) At 2 weeks G1: 4.6 (0.97 G2: 3.8 (1.48) G3: 3.9 (0.99) 2 week follow-up G1: 4.75 (1.16) G2: 4.00 (1.15) G3: 3.7 (1.57) | Quality of Life NR Adverse Events NR Attrition Overall, % at 2 weeks 0%, during two week follow-up 3 patents withdrew due to changes in pharmacotherapy At end of treatment, % G1: 0 G2: 0 G3: 0 At end of follow-up, % NR Does not report which group 3 patients came from Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR rTMS+SPECT received active rTMS that was focused on different regions of brain after examination with single photon emission computed tomography (20- At end of treatment, % G1: 0 G2: 0 G3: 0 At end of follow-up, % NR Does not report which group 3 patients came from Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR rTMS+SPECT received active rTMS that was focused on different regions of brain after examination with single photon emission computed tomography (20-Hz rTMS to an area of relatively low activity and 1-Hz rTMS to an area showing relatively high activat Adherence/ compliance Compliance all patients completed active 2 week treatment
Author, Year Holtzheimer et al., 2004^19^ Country, setting USA, single center, outpatient/inpatient status not clearly stated Funding University of Washington Research Objective Initial hypotheses that rTMS would have greater antidepressant effects than sham stimulation and that rTMS would be safe and tolerable Quality Rating Fair | Study design RCT Type of analysis ITT N 15 Duration Primary endoint following 2 weeks of treatment and follow-up 1 week after txt completed Interventions G1: rTMS G2: Sham Medications Allowed All pts discontinued (failed) AD medication Strategy Switch Parameters rTMS; - Frequency (Hz): 10; - Motor threshold (%): 110; - Number of trains:32; - Length of train (seconds): 5; - Inter-train interval: 30-60; Pulses per session: 1600; - Total number of sessions: 10 over 2 wks; Sham rTMS; - Delivered in same anatomical location with identical stimulation parameters, but with lateral edge of coil rotated 45 degrees away from scalp | TRD definition; - Subjects must have failed at least two previous antidepressant trials due to lack of response to an adequate trial (defined by ATHF) or medication intolerance; - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - 21 to 65 years of age; - Right-handed; - Meet DSM-IV criteria for a major depressive episode due to MDD; - HAM-D17 ≥ 18; Exclusion criteria; - No other major psychiatric or medical comorbidity; - History of Bipolar Disorder; - Previous failure of ECT; - History of substance abuse or dependence; - Current symptoms of psychosis; - Pregnancy | Treatment Failure Failed 7 or more, % G1: 85.7 G2: 37.5 Polarity, % Unipolar 100% MDD Age, mean yrs G1: 40.4 G2: 45.4 Sex, % females G1: 57.1 G2: 42.9 Right handed, % G1: 100 G2: 100 HAM-D 17 Baseline n G1: 7 G2: 8 Baseline score, mean (SD) G1: 22.7 (5.3) G2: 20.8 (6.3) BDI Baseline score, mean (SD) G1: 29.6 (10.0) G2: 28.5 (10.6) | HAM-D 17 Endpoint score, mean (SD) At week 1 G1: 18.0 (1.2) G2:18.0 (2.7) At week 2 G1: 14.6 (3.2) G2: 15.3 (3.0) 1 week follow-up G1: 18.8 (2.5) G2: 17.6 (2.1) Change, mean (SD) At week 1 G1: 4.7 G2: 2.8 At week 2 G1: 8.1 G2: 5.5 1 week follow-up G1: 3.9 G2: 3.2 All endpoints, P = NS Responders, n (%) At week 1 G1: 0 G2: 0 At week 2 G1: 2 (28.6) G2: 1 (12.5) 1 week follow-up G1: 0 G2: 0 BDI Endpoint score, mean (SD) At week 1 G1: 27.5 (3.2) G2: 24.9 (2.7) At week 2 G1: 23.9 (2.6) G2: 22.4 (2.4) 1 week follow-up G1: 23.9 (1.6) G2: 26.4 (1.9) Change, mean (SD) At 2 weeks G1: 5.7 G2: 6.1 Change, mean (SD) 1 week follow-up G1: -5.7 G2: -2.1 Group × time (all points), P = NS | Quality of Life NR Adverse Events No major adverse events at any point in study. Some subjects experienced mild pain with active rTMS, but treatments were generally tolerated. Neuropsychological or executive functioning Both groups performed equally well with exception of one measure of verbal memory, Trial 7 of Rey Auditory Verbal Learning Test, in which subjects that received rTMS performed slightly better (rTMS: mean score = 12.7 (2.1) vs.: sham mean score = 12.0 (2.3); P < 0.05). No acute changes in level of consciousness, orientation, or short-term memory associated with any rTMS or sham treatments sessions. MMSE NR There were no major adverse events at any point in study. Some subjects experienced mild pain with active rTMS, but treatments were generally well tolerated. Attrition Overall, % 0 during treatment. 3 (20%) before final assessment at week 3 At end of treatment, % 0 At end of follow-up, % G1: 28.6 G2: 12.5 Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR Other NR Adherence/ compliance Compliance All 15 subjects completed all 10 txt sessions

Evidence Table 23 KQ 4. General Tolerability: Tier 1 (rTMS vs . sham—MDD/Bipolar)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Boutros et al., 2002^13^ Country, setting US, Yale School of Medicine and VA-Connecticut, outpatient Funding VA Merit Award & K24 DA00520-01A1/DA/NIDA NIH HHS; 1 author employee of Pfizer Research Objective To provide additional data on efficacy and safety for rTMS as an augment strategy in TRD Quality Rating Fair | Study design RCT Type of analysis ITT N 21 Duration 2 weeks txt; follow-up with responders for up to 20 weeks post txt Interventions G1: rTMS G2: Sham Medications Allowed Pts allowed to continue all current psychotropic meds Strategy Augmentation, 3 pts in active and 1 in sham txt were not on any meds Parameters rTMS:; - Frequency (Hz):20; - Motor threshold (%): 80; - Number of trains: 20; - Length of train (seconds): 2; - Inter-train interval: 58; - Pulses per session: 800; - Total number of sessions: 10 over 10 weekdays; Sham:; - Coil angled 90 degrees to scalp; - 1 wing of figure 8 touching scalp | TRD definition; - 2+ failed trials of adequate dose and durations; - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - Major Depression; - HAM-D25 >= 20; Exclusion criteria; - Suicidality; - “Prominent” psychotic symptoms; - History of neurological disorders; - Current drug abuse | Treatment Failure Mean failed trials NR Polarity, % Unipolar Overall: 100% Age, mean yrs G1: 49.5 G2: 52.0 Sex, % females G1: 25 G2: 10 Right handed, % G1: 90.9 G2: 88.9 HAM-D Baseline n G1: 12 G2: 9 Baseline score, mean (SD) G1: 34.4 (10.1) G2: 31.7 (4.9) | HAM-D Endpoint score, mean (SD) At 2 weeks G1: 29.0 G2: 28.11 Change, mean (SD) G1: -11.75 G2: -6.22 P = NS Responders, n Defined as 30% improvement on HAM-D G1: 7 G2: 2 Responders, n (%) Defined as 50% improvement on HAM-D G1: 3 G2: 2 Relapse Of 6 active treatment responders included in 20-week follow-up (no continuing intervention), 4 relapsed. Of 1 sham responder included in the 20-week follow-up, 1 relapsed | Quality of Life NR Adverse Events Overall, % G1: (% of pts reporting AEs) 66.7 G2: 55.6 Cognitive impairment, % Difficulty concentrating (phase 1 only) G1: 25 G2: NR Headache, % “most frequent complaint” % NR Other:; - scalp tenderness at site of stimulation: 25%, 11.1%; - hearing problem: 8.3%, NR;; - diarrhea: 8.3%, NR; Attrition Overall, % 18.2% (4/22) At end of treatment, % G1: 8.3 (1/12) G2: 30.0 (3/10) At end of follow-up, % NR Withdrawals due to efficacy, %: NR Withdrawals due to adverse events, %: NR Adherence/ compliance NR
Author, Year Fitzgerald et al., 2006^14^ Country, setting Australia, single center Funding Australian National Health and Medical Research Council and by Constance and Stephen Lieber through a National Alliance for Research on Schizophrenia and Depression Lieber Young Investigator award (to Dr. Fitzgerald) Research Objective rTMS versus placebo for depression Quality Rating Fair | Study design RCT Type of analysis ITT (LOCF) N 50 Duration 2 wks double blind with those with >20% decrease in MADRS to continue treatment for up to 6 wks with active or sham txt (LOCF for all pts); sham pts with inadequate response were allowed to enter open label txt. Primary outcome after 2 and 6 weeks of txt Interventions G1: rTMS G2: Sham Medications allowed; - Stable medications allowed; - SSRIs, SNRIs, Tricyclics ADs; - Mood stabilizers,; - Lithium,; - Anticonvulsants,; - Antipsychotic medication,; - Benzodiazepines; Strategy Augmentation, 23% not taking medication at study entry Parameters rTMS Low Right: Frequency (Hz):1; - Motor threshold (%): 110; - Number of trains: 3; - Length of train (seconds): 140; - Inter-train interval: 180; - Pulses per session: 420 rategy; Sequential High Left:; - Frequency (Hz): 10; - Motor threshold (%): 100; - Number of trains: 15; - Length of train (seconds): 5; - Inter-train interval: 25; - Pulses per session: 750; - Total number of sessions: 10 sessions 5 days/wk; Sham:; - Coil angled at 45 degrees off head. Medial wing of coil was resting on scalp; - Stimulation parameters identical to those for active treatment (both sides | TRD definition; - 2+ failed medications with txt duration ≥6 wks; - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - DSM-IV diagnosis of Major Depressive Episode; - MADRS ≥ 20; Exclusion criteria; - Significant medical illness; - Neurological disorders; - Other axis I psychiatric disorders | Treatment Failure Mean failed AD trials (lifetime) G1: 5.6 (3.1) G2: 6.2 (3.0) Polarity, % Unipolar G1: 84% G2: 84% Bipolar G1: 16% G2: 16% Age, mean yrs G1: 46.8 G2: 43.7 Sex, % females G1: 60 G2: 64 HAM-D 17 Baseline n G1: 25 G2: 25 Baseline score, mean (SD) G1: 22.5 (7.4) G2: 19.8 (4.4) BDI Baseline n G1: 25 G2: 25 Baseline score, mean (SD) G1: 29.2 (18.3) G2: 29.3 (9.9) MADRS Baseline n G1: 25 G2: 25 Baseline score, mean (SD) G1: 34.0 (5.9) G2: 34.1 (5.2)RS Baseline n | HAM-D 17 Endpoint score, mean (SD) NR Change, % decrease (SD) G1: 45.2% (40.1) G2: 5.4% (23.1) P < 0.001 Change, mean G1: -10.17 G2: -1.07 Responders, n (%) At 6wks G1: 13 (52.0) G2: 2 (8.0) P = 0.001 Remitters, n At 6wks G1: 10 (40.0) G2: 0 (0) P = NR BDI Endpoint score, mean (SD) At week 2 G1: 18.3 (10.3) G2: 221.6 (13.7) At 4 weeks G1: 10.5 (8.3) G2: 21.0 (19.8) At 6 weeks G1: 9.2 (6.7) G2: NR Change, mean (SD) At week 2 G1: 10.9 G2: 7.7 At 4 weeks G1: 18.7 G2: 8.3 At 6 weeks G1: 20.0 G2: NR, P = 0.01 Responders, n NR Remitters, n NR MADRS Endpoint score, mean (SD) At week 2 G1: 26.2 (10.2) G2: 30.9 (8.2) At week 4 G1: 11.7 (7.1 G2: 34.5 (12.0) At week 6 G1: 8.9 (7.9) G2: NA Change, mean (SD) At week 2 G1: 7.8 G2: 3.2 At week 4 G1: 22.3 G2: 0.4 (increased) At week 6 G1: 25.1 G2: NA Group by time, P = 0.001 at all time points Responders, n At 6 weeks G1: 11 G2: 2 P < 0.05 Remitters, n MADRS < 10 At 6 weeks G1: 9 G2: 0 P = 0.005 At week 2 G1: 2 G2: 0 Follow-up at week 3 G1: 3 G2: 0 Follow-up at week 4 | Quality of Life GAF Baseline n G1: 25 G2: 25 Baseline score, mean (SD) G1: 48.8 (8.2) G2: 49.0 (4.9) Endpoint score, mean (SD) G1: 59.0 (16.5) G2: 50.1 (10.3) [P <0.05] Change, mean (SD) G1: 10.2 G2: 1.1 GAF Scale (t=2.0, df=40.2, P < 0.05) Adverse Events Headache, % G1: 20 G2: 8 Nausea 12% vs. 0, No seizures or manic episodes; Hopkins Verbal Learning Test performance decreased for both groups with no group by time interaction. Performance improved on digit span backward test improved in rTMS only (group by time: P = 0.07). Controlled Oral Word Association test improved for both groups (time: P = 0.001). Nausea 12% vs. 0, No seizures or manic episodes; Neuropsychological or executive functioning Hopkins Verbal Learning Test Performance decreased for both groups with no group by time interaction Digit span backward Test Performance improved in rTMS only (group by time: P = 0.07). Controlled Oral Word Association Test Improved for both groups P = 0.001 MMSE NR Other Nausea 12% vs. 0 No seizures or manic episodes; Attrition Overall, % At 2 weeks: 6 At 3 weeks: 56 At 4 weeks: 70 At 5 weeks: 78 At 6 weeks: 78 After initial 2 weeks, patients that did not have a 10% reduction on a weekly assessment were withdrawn At end of treatment, % G1: 0 G2: 12 At end of follow-up, % G1: 56 G2: 100 Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR Adherence/ compliance NR
Author, Year Fitzgerald et al., 2003^15^ Country, setting Australia 2 general psychiatric services, outpatients Funding National Health and Medical Research Council and a grant from Stanley Medical Research Institute Research Objective To evaluate efficacy of HFL-TMS and LFR-TMS in treatment-resistant depression and compared with a sham-treated control group Quality Rating Good | Study design RCT Type of analysis ITT N 60 Tier 1 Duration Primary endpoint after 2 weeks of txt, after which pts with <20% reduction in MADRS could cross over to the other active txt. Follow-up assessment conducted at 2 weeks post txt. Interventions G1: High Frequency rTMS G2: Low Frequency rTMS G3: Sham Medications Allowed 46 patients continued (failed) AD medication while others were not on a med at study entry. Patients allowed mood stabilizers and antipsychotics Strategy Augmentation Parameters rTMS LowFrequency (Hz):1; - Motor threshold (%): 100; - Number of trains: 60; - Length of train (seconds): 5; - Inter-train interval:60; - Pulses per session: 300; - Total number of sessions: 10 sessions daily, 5 days/week; rTMS High; - Frequency (Hz):10; - Motor threshold (%): 100; - Number of trains: 20; - Length of train (seconds): 5; - Inter-train interval: 25; - Pulses per session: 1000; - Total number of sessions: 10 sessions daily, 5 days/week; Sham rTMS; - Coil angled 45 degrees offhead for 10 sessions daily, 5 days/week | TRD definition; - Failed a minimum of 2 courses of antidepressant medications (6+ weeks); Not required or not specified to be in current episode Inclusion criteria; - DSM-IV diagnosis of Major Depression (included bipolar depression); Exclusion criteria; - Significant medical illnesses, neurologic disorders, or other Axis I psychiatric disorders | Treatment Failure Mean failed trials Overall (SD) 5.68 (3.40) Polarity, % Bipolar I G1: 5 G2: 5 G3: 20 Age, mean yrs G1: 42.2 G2: 45.55 G3: 49.15 Sex, % females G1: 40 G2: 35 G3: 55 Right handed, % G1: 90 G2: 100 G3: 85 BDI Baseline n G1: 20 G2: 20 G3: 20 Baseline score, mean (SD) G1: 33.15 (12.12) G2: 35.05 (9.25) G3: 32.30 (9.10) MADRS Baseline n G1: 20 G2: 20 G3: 20 Baseline score, mean (SD) G1: 36.05 (7.55) G2: 37.70 (8.36) G3: 35.75 (8.14) | BDI Endpoint score, mean (SD) At 2 weeks G1: 26.7 (11.9) G2: 27.2 (10.8) G3: 29.0 (8.7) Change, mean (SD) At 2 weeks G1:- 6.4 G2: -7.8 G3: -2.3 P = 0.03 MADRS Endpoint score, mean (SD) At 2 weeks G1: 30.8 (7.8) G2: 32.2 (9.0) G3: 35.4 (7.5) Change, mean; % change, (SD) At 2 weeks G1: -5.25; 13.5 % (16.7%) G2: -5.5; 15.0% (14.1%) G3: -0.35; 0.76% (16.2%) P = 0.004 G1: vs. G3, G2 vs. G3, P < 0.005 Responders, n 20% ≤ decrease At 2 weeks G1: 8 (40) G2: 7 (35) G3: 2 (10) P = 0.07 Responders, n 50% ≤ decrease At 2 weeks G1: 0 G2: 1 (5) G3: 0 P = NR CGI Endpoint score, mean (SD) NR P =.01 | Quality of Life GAF Global Assessment of Functioning Baseline n G1: 20 G2: 20 G3: 20 Baseline score, mean (SD) G1: 43.00 (6.76) G2: 43.55 (9.94) G3: 42.75 (7.15) Endpoint score, mean (SD) At 2 weeks G1: 45.2 (7.1) G2: 46.3 (8.5) G3: 42.5 (6.8) Change, mean (SD) At 2 weeks G1: 2.2 G2: 2.85 G3: 0.5 Overall group F56,2=2.6; P =.08; LFR-TMS vs. sham: P = 0.03; and HFLTMS vs. sham: P = 0.09 Quality of Life Overall group F56,2=2.6; P =.08; LFR-TMS vs. sham: P = 0.03; and HFLTMS vs. sham: P = 0.09 Adverse Events Dizziness, % G1: 5% G2: 5% G3: 0 G4: 3.3% Other: 0- 2wks: 7 (11%) of 60 patients reported site discomfort or pain during rTMS and 6 (10%) reported a headache after rTMS. Although there was no difference in incidence of these adverse effects (P =.08), patients inHFL-TMS group seemed to report more discomfort during procedure itself. Only 1 patient (HFL-TMS group) reported persistence ofheadache for longer than 1 hour. Two patients (1 in each group) reported transient dizziness for a short time after treatment. 2wks - 4 wks: One patient withdrew after 1 session of HFL-TMS treatment insingle-blind phase ofstudy owing to site pain. One bipolar patient, who had a successful response to LFR-TMS treatment, experienced a manic episode 10 days after completion of trial after ceasing treatment with valproate sodium Neuropsychological or executive functioning; - No deterioration in performance was found in any cognitive measures in group as a whole or in analyses of patients who received HFL-TMS only LFR-TMS only, or both active treatment conditions; - Including all patients who underwent at least 1 type of active treatment, there was a significant improvement in performance onverbal paired associates (t50=−7.3; P < 0.001), verbal fluency (t48=−3.8; P < 0.001), and digit span forwards (t48=−1.8; P = 0.003) subscales;Personal Semantic Memory Schedule (t50=−2.4; P = 0.02); andAutobiographical Memory Schedule (t50=−1.9; P = 0.05).; - A similar pattern of improvements was seen for each oftreatment subgroups (HFL-TMS only, LFR-TMS only, or both active treatments).; - Changes in performance oncognitive measures did not correlate with changes in MADRS and Beck Depression Inventory scores acrosssame times.; MMSE NR Other Attrition Overall, % None in initial 2 week treatment phase At end of treatment, % 0 At end of follow-up, % NR But at least 28.3% did not continue on thru2nd 2 weeks Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % G1: 0 (1 during follow-up) G2: 0 (0 during follow-up) G3: 0 (0 during follow-up) Progression of patients through 2nd phase is very unclear
Author, Year Su et al., 2005^26^ Country, setting Taiwan, NS Funding Taipei Veterans General Hospital, patient status not reported Research Objective To investigate whether two weeks of rTMS applied toLDLPFC can alleviate TRD Quality Rating Fair | Study design RCT Type of analysis Completers N 33 Duration 2wk of active txt Primary outcome: HAM-D at 2 weeks (after 10 txt) Interventions B - Repetetive Transcranial Magnetic Stimulation (rTMS)E -Placebo G1: 20Hz rTMS (N analyzed = 10) G2: 5Hz rTMS (N analyzed = 10) G3: Sham (N analyzed = 10) Medications allowed pts allowed to continue all meds constant for 4 weeks prior (e.g. antidepressants, antipsychotics, mood stabilizers, or stimulant Strategy Augmentation Parameters rTMS High:; - Frequency (Hz): 20; - Motor threshold (%): 100; - Number of trains:40; - Length of train (seconds):2; - Inter-train interval:28; - Pulses per session: 1600; - Total number of sessions: 5/wk or 10 in 10 weekdays; rTMS Low:; - Frequency (Hz): 5; - Motor threshold (%): 100; - Number of trains: 40; - Length of train (seconds): 8; - Inter-train interval: 22; - Pulses per session: 1600; - Total number of sessions:5/wk or 10 in 10 days; Sham:; - Same as high frequency rTMS.; Coil placed at 90 degrees off skull. | TRD definition; - TRD (2+ failed adequate trials); - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - Major Depressive Episode or Bipolar (DSV-IV),; - Ham-D21 score >=18; Exclusion criteria; - history of - epilepsy,; - any physical and neurological abnormalities, major head trauma,; - psychotic symptoms;; - current use of a pacemaker,; - suicidality | Subgroups Ethnicity - Chineese, females by menopausal status Treatment Failure Mean failed trials NR Polarity, % Unipolar G1: 90 G2: 80 G3: 80 Bipolar G1: 10 G2: 20 G3: 20 Bipolar II G1: 10 G2: 10 G3: 10 Age, mean yrs G1: 43.6 G2: 43.2 G3: 42.6 Sex, % females G1: 70 G2: 80 G3: 70 HAM-D 17 Baseline N G1: 10 G2: 12 G3: 11 Baseline score, mean (SD) G1: 23.2 (7.5) G2: 26.5 (5.2) G3: 22.7 (4.7) BDI Baseline score, mean (SD) G1: 28.0(9.1) G2: 33.9(7.6) G3: 33.4(9.6) CGI-S Baseline score, mean (SD) G1: 4.5(0.7) G2: 4.7(0.8) G3: 4.7(0.48) | HAM-D 17 N analyzed G1: 10 G2: 10 G3: 10 Endpoint score, mean (SD) At 2 weeks G1: 12.8(6.7) G2: 12.3(7.7) G3: 19.0(7.7) Change, mean (SD) At 2 weeks G1: -13.4(4.9) G2: -14.2(6.0) G3: -3.7(9.3) G1: vs. G3, G2 vs. G3 P < 0.01 Responders, n G1: 6 (60) G2: 6 (60) G3: 1 (10) G1: + G2 vs. G3 P = 0.01 Remitters, n Ham-D17<= 7 G1: 5 (50) G2: 5 (50) G3: 0 BDI Endpoint score, mean (SD) At 2 weeks G1: 12.8(6.7) G2: 19.7(12.3) G3: 28.7(15.1) Change, mean (SD) At 2 weeks G1: 15.2(7.5) G2: 14.2(10.4) G3: 4.7(9.1) G1: vs. G3 P <0.05 G2 vs. G3 P <0.1 CGI-S Endpoint score, mean (SD) At week 2 G1: 2.8(1.1) G2: 2.0(0.9) G3: 3.6(1.1) Change, mean (SD) G1: -1.7 G2: -2.0 G3: -1.1 P = NS | Quality of Life NR Adverse Events Headache, % G1: 20 (n=2) G2: 20 (N=2) G3: 11.1 (N=1) Pain at rTMS site: 16.7% withdrew due to pain at stimulation site SEE AE section Attrition Overall, % 9.1 (3/33) At end of treatment, % G1: 0 G2: 16.7 G3: 9.1 At end of follow-up, % NR Withdrawals due to efficacy, % G1: 0 G2: 0 G3: 9.1 Withdrawals due to adverse events, % G1: 0 G2: 16.7 G3: 0 1 dropped out of sham for worsening of clinical symptoms, this was categorized as LOE Adherence/ compliance NR

Evidence Table 24 KQ 4. General Tolerability: Tier 1 (VNS vs. sham—MDD/Bipolar)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Rush et al., 2005^24^ Carpenter et al., 2004^25^ Country, setting US, multicenter, outpatient psychiatric Funding Cyberonics, Inc. Research Objective To compare adjunctive VNS to sham in TRD patients Quality Rating Good | Study design RCT Type of analysis m-ITT/PP for efficacy, ITT for Aes N 235 Duration 10wks of stimulation Primary Outcome: HAM-D Response after 10wks txt Interventions G1: VNS G2: Sham Medications allowed pts allowed up to 5 antidepressants, mood stabilizers, or other psychotropic medications Strategy Augmentation Parameters VNS: Frequency (Hz): 20 Pulse width (seconds): 500 μs; - On/Off cycle parameters: 30 sec on and 5 min off; - Duration of treatment:; Sham:; - Device implanted but not turned on | TRD definition; - TRD (2-6 failures verified by the ATHF, with failures in tw different drug classes); - Required to be in current episode; Tier 1 Inclusion criteria; - Current Major Depressive Episode (MDE) of 2+ yrs OR 4+ MDE in lifetime,; - age 18-80, HAM-D24>=20;; - bipolar pts had to also be resistant, intolerant of, or have contraindications to lithium; Exclusion criteria; - Atypical or psychotic features in any MDE; - current rapid cycling bipolar disorder, delerium, dementia, amnesia; - other cognitive disoder, suicidality; - risks related to surgical implantation | Treatment Failure Percent with 4-6 current episode failures G1: 46.5% G2: 40.0% Polarity, % Unipolar G1: 88.4 G2: 90.9 Bipolar I G1: 5.4 G2: 3.6 Bipolar II G1: 6.3 G2: 5.5 Age, mean yrs G1: 47.0 G2: 45.9 Sex, % females G1: 59 G2: 66 Race, % white G1: 97 G2: 96 HAM-D24 Baseline n G1: 119 G2: 116 Baseline score, mean (SD) G1: 28.8(5.3) G2: 29.7(5.2) MADRS Baseline score, mean (SD) G1: 31.4(6.3) G2: 31.9(6.3) IDS Baseline n G1: 112 (115 randomized) G2: 110 Baseline score, mean (SD) G1: 44.3(9.1) G2: 45.4(8.5) CGI-I Baseline n G1: 112 G2: 110 | HAM-D24 N analyzed G1: 112 G2: 110 Endpoint score, mean (SD) NR % change, mean (SD) G1: -16.3 (28.1) G2: -15.3 (25.5) P = 0.639 Responders, n G1: 17 (15.2%) G2: 11 (10.0%) P = 0.251 MADRS Endpoint score, mean (SD) NR % change, mean (SD) G1: -17.1 (31.2) G2: -12.4 (27.1) P = 0.208 Responders, n G1: 17 (15.2) G2: 12 (0.0) P = 0.378 IDS Endpoint score, mean (SD) NR % change, mean (SD) G1: 21.2 (25.4) G2: 16.3 (26.2) P = 0.158 Responders, n G1: 19 (17) G2: 8 (7.3) P = 0.032 Remitters, n NR CGI-I Endpoint score, mean (SD) NR Achieving 1 or 2 score, %(SD) G1: 13.9 G2: 11.8 VNS v. Sham, P = 0.648 | Quality of Life Medical Outcomes Study Short Form-36 (MOS-SF36) Baseline n G1: 112/ N=107 QOL analysis G2: 110/ N=107 QOL analysis Baseline score, mean (SD) NR Endpoint score, mean (SD) NR Change, mean (SD) G1: physical component: -0.9 (8.3); mental component: 5.0 (11.6) G2: physical component -1.6(8.4); mental component: 4.0(10.2) Other Physical component between VNS and sham: P = 0.480, Mental Component between VNS and sham: P = 0.406 Adverse Events Overall, % NR Cardiovascular adverse events, % G1: 5, palpitations 5 G2: 3 Other:–; - voice alteration: 68% v 38%; - cough increased: 29% v 9%; - dyspnea: 23% v 14%,; - dysphagia: 21% v 11%,; - neck pain: 21% v 10%,; - paresthesia: 16% v 10%,; - vomiting: 11% vs. 12%,; - laryngismus 11% v 2%,; - dyspepsia 10 v 5; - wound infection 8% v 2%,; - hypomania/mania (via Young Mania Scale): 1.7% (1pt with a prestudy dx of bipolar) v 0%; Overall SAEs 30, pts VNS: 13.4% (16/119). Sham: 12.1% (14/116) 12 events, involving 11 patients, were cases of worsening depression requiring hospitalization Cardiac SAEs during implantation: 1.7% v 0% COSTART used to code reported events Attrition Overall, % 1.3 (3/235) At end of treatment, % G1: 2.6 G2: 0 At end of follow-up, % NR Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % G1: 2.6 G2: 0 9 pts had a protocol violation post randomization Adherence/ compliance NR

Evidence Table 25 KQ 4. General Tolerability: Tier 2 (rTMS vs. sham—MDD only)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Stern et al., 2007^32^ Country, setting NR, outpatient setting Funding The Milton Fund, NARSAD,Stanley Vada NAMI Foundation, NIMH, Spanish Ministerio de Educacion y Cienca Research Objective To test hypothesis that rTMS exerts antidepressant effects either by enhancing left dorsolateral prefrontal cortex (DLPFC) excitability (using high-frequency rTMS) or by decreasing right DLPFC excitability (using low-frequency rTMS) have equivalent an Quality Rating Fair | Study design RCT Type of analysis Cannot tell, all reported patients included in the analysis N 45 Duration; - 10 days (2 wk) stimulation and 2 wk f/u for all 4 gps; - An additional 2 wk of unblinded f/u with gp 1 & 3 to assess for relapse.; Primary Outcome: HAM-D at 2 weeksnd and 2 weeks after treatment Interventions G1: 10 Hz rTMS to left DLPFC G2: 1 Hz rTMS to left DLPFC G3: 1 Hz toright DLPFC G4: Sham rTMS Medications allowed No psychotropic medications were allowed Parameters rTMS High Frequency:; - Frequency (Hz):10; - Motor threshold (%): 110; - Number of trains: 20; - Length of train (seconds): 8; - Inter-train interval: 52; - Pulses per session: 1600; - Total number of sessions: 10; Low Frequency LDLPFC:; - Frequency (Hz):1; - Motor threshold (%): 110; - Number of trains: 1; - Length of train (seconds): 1600; - Inter-train interval: 1; - Pulses per session: 1600; - Total number of sessions: 10; Low Frequency RDLPFC:; - Frequency (Hz): 1; - Motor threshold (%): 110; - Number of trains: 1; - Length of train (seconds): 1600; - Inter-train interval: 1; - Pulses per session: 1600; - Total number of sessions: 10; Sham rTMS:; - Orientation of coil perpendicular to scalp subdivided into 3 groups, replicating parameters for each group above; Strategy Switch Number of trains: 1; - Length of train | TRD definition; - All referred for ECT having failed an adequate course of antidepressant med; - Required to be in current episode; Tier 2 Inclusion criteria; - Patients w unipolar recurrent major depressive disorder (SCID & DSM-IV) HAM-D21 score ≥ 20; Exclusion criteria; - H/O any psychotic disorder (incl. schizophrenia or schizoaffective disorder); - Bipolar disorder; - Obsessive compulsive disorder; - Personality disorder; - SA(except nicotine) within past yr; - Current acute/chronic medical condition requiring txt with psychoactive medication; - H/O epilepsy or unprovoked seizures or other neurological disorder; - Abnormal neurological examination; - Family H/O medication-resistant epilepsy; - Prior brain surgery; - Metal in head; - Implanted medical device; - Pregnancy | Treatment Failure Mean failed trials NR Polarity, % Unipolar 100 % MDD Age, mean yrs G1: 53.2 G2: 52.3 G3: 52.8 G4: 53.3 Sex, % females G1: 60 G2: 60 G3: 70 G4: 60 Right handed, % 100 HAM-D 21 Baseline n G1: 10 G2: 10 G3: 10 G4: 15 Baseline score, mean (SD) G1: 27.8 (3.2) G2: 27.6 (3.9) G3: 27.9 (3.8) G4: 27.4 (2.9) | HAM-D 21 Endpoint score, mean (SD) At week 1 G1: 22.2 (5.6) G2: 27.6 (5.9) G3: 20.9 (4.1) G4: 25.6 (4.5) At week 2 G1: 15.1 (6) G2: 27.6 (5.9) G3: 15.8 (4.8) G4: 26.7 (3.6) Week 1 Follow-up G1: 12.8 (5.7) G2: 26.4 (2.3) G3: 15.3 (6.4) G4: 26.5 (2.3) Week 2 Follow-up G1: 13.4 (5.6) G2: 26.6 (3.0) G3: 14.9 (5.9) G4: 26.8 (2.3) Change, mean (SD) At week 2 G1: -12.7 G2: 0.0 G3: -12.1 G4: -0.7 % change, P = 0.001 2 week follow-up G1: 0 G2: 1.0 G3: 13.0 G4: 0.6 % change, P = 0.00001 Responders, n At week 1 G1: 0 G2: 0 G3: 0 G4: 0 At week 2 G1: 2 (50%) G2: 0 (0%) G3: 5 (50%) G4: 0 (0%) G1/G3 vs. G2/G4 (P < 0.0005) 1 week follow-up G1: 6 (60%) G2: 0 (0%) G3: 6 (60%) G4: 0 (0%) G1/G3 vs. G2/G4 (P < 0.0005) 2 week follow-up G1: 4 (40%) G2: 0 (0%) G3: 6 (6%) G4: 0 G1/G3 vs. G2/G4 (P < 0.0005) Remitters, n HAM-D ≤ 10 At week 1 G1: 0 (0%) G2: 0 (0%) G3: 0 (0%) G4: 0 (0%) At week 2 G1: 3 (30%) G2: 0 (0%) G3: 1 (10%) G4: 0 (0%) 1 week follow-up G1: 4 (40%) G2: 0 (0%) G3: 3 (30%) G4: 0 (0%) 2 week follow-up G1: 4 (40%) G2: 0 (0%) G3: 3 (30%) G4: 0 (0%) Responders followed for additional two weeks (endpoint 2wk follow-up) G1: vs. G3 P = NS (all times); G2 vs. G4 and G1: vs. G3 P = NS (all times) | Quality of Life NR Adverse Events 9/45 pts reported severe headaches (pts by group NR); no seizures Attrition Overall, %: 17.8 At end of treatment, % G1: 0 G2: 20 G3: 0 G4: 10 At end of follow-up, % G1: 0 G2: 50 G3: 0 G4: 20 Withdrawals due to efficacy: NR Withdrawals due to adverse events, % G1: 0 G2: 50 G3: 0 G4: 20 Though 8 pts withdrew due to AE, only 3 of those were listed as w/d during active period. Reported in text as dropped out following week 2. Adherence/ compliance NR

Evidence Table 26 KQ 4. General Tolerability: Tier 2 (CBT vs. usual care—MDD/Bipolar)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Harley, 2008^36^ Country, setting United States, university clinics, outpatient psychiatric Funding Kaplan Fellowship Award Grant through Harvard Medical School Research Objective To assess feasibility and potential utility of a Dialectical Behavior Therapy(DBT)-based skills training group for TRD Quality Rating Fair | Study design RCT Type of analysis Completers N 24 Duration Primary outcome after 16 weeks of active txt Follow-up: 6 months Interventions G1: Dialectical Behavior Therapy(DBT)-based skills training G2: Wait-list Control Medications Allowed Patients continued antidepressant therapy Strategy Augmentation Parameters; - Type of therapy: Dialectical Behavior Therapy(DBT)-based skills training; - Method: Group; - Number of sessions/week:1; - Total number of sessions:16; G2: Wait list | TRD definition; - 1+ failed medications (6+ weeks at “standard effective dose”); - Not required or not specified to be in current episode; Tier 2 Inclusion criteria; - 18-65 years with a principal diagnosis of MDD; - Established treatment relationship with a psychiatrist at MGH or in larger community.; - Stabalized on an adequate dose of antidepressant medication before entering study.; Exclusion criteria; - Borderline personaliy disorder, bipolar disorder, psychotic spectrum disorders, active substance abuse or dependence, mental retardation, or pervasive developmental disorder.; - Active suicidality requiring more intensive levels of care; - Severe or unstable medical conditions; - Previous or current CBT experience | Baseline N G1: 13 G2: 11 Treatment Failure Mean failed trials NR Polarity, % MDD Overall: 100 Age, mean yrs Overall: 41.8 Sex, % females Overall: 75 Race, % white Overall: 83 HAM-D 17 Baseline score, mean (SD) G1: 16.15 (4.47) G2: 18.64 (4.72) P = NS BDI Baseline score, mean (SD) G1: 27.31 (8.83) G2: 27.44 (11.66) P = NS | HAM-D 17 Analyzed n G1: 10 G2: 9 Endpoint score, mean (SD) Completers analysis, 16 weeks G1: 11.30 (5.3) G2: 17.11 (6.23) Change, mean (SD) Completers, 16 weeks G1: -5.6 G2: -1.78 P < 0.05 Remitters, n Completers per protocol analysis, 16 weeks G1: 3 (23%*) G2: 0 (0%*) P = NR BDI Endpoint score, mean (SD) At Week 16, completers per protocol G1: 15.10 (12.13) G2: 25.89 (16.30) Change, mean (SD) G1: -12.80 G2: -1.55 P < 0.01 | Quality of Life Lifework-The Range of Impaired Functioning Tool (LIFE-RIFT) Baseline n G1: 10 G2: 9 Baseline score, mean (SD) G1: 4.00 (0.94) G2: 3.44 (1.24) Endpoint score, mean (SD) G1: 2.70 (1.34) G2: 3.11 (1.69) Change, mean (SD) G1: -1.3 G2: -0.33 P = NS Social Adjustment Scale-Self-Report (SAS-SR) work subscale Baseline n G1: 10 G2: 9 Baseline score, mean (SD) G1: 82.50 (21.21) G2: 69.22 (17.95) Endpoint score, mean (SD) G1: 65.70 (19.27) G2: 69.56 (17.66) Change, mean (SD) G1: -16.80 G2: 0.34 P < 0.05 Adverse Events NR MMSE NR Attrition Overall, %: 21 At end of treatment, % G1:23 G2:18 At end of follow-up, % G1:20 G2: NR Withdrawals due to efficacy, % G1: 8 G2: 0 Withdrawals due to adverse events, % 0 Other 5 participants (3 groups, 2 wait-lists) did not complete study. One group participant dropped out because of difficulty finding childcare another discontinued treatment due to a work schedule conflict, and third decided group was not a good fit. One wait-list participant moved and could not continue in study and a medical problem prevented second from continuing. Adherence/ compliance Compliance Participants completed a weekly check-in form asking about medication compliance over preceding month.19 participants who completed study reported that they had been largely medication compliant—11 reported that they had taken their medication as directed every day and 8 reported that they had forgotten a medication dose between 1 to 4 times in previous month.
Author, Year Paykel, 1999^38^ Scott, 2000^59^ Note: #2223 and #2219 are companion studies, data from #2223 were abstracted in to form for #2219. Country, setting UK, outpatient Funding Medical Research Council, London, England and a grant from Oxford and Anglia Region Research Objective To compare cognitive therapy combined with clinical management to clinical management alone for patients with residual depressive symptoms who continued to receive maintenance treatment with antidepressants. Quality Rating Good | Study design RCT Type of analysis ITT N 158 Duration Treatment period = 20 weeks; 48 wks - follow-up: Subjects were assessed every 4 to 20 wks and every 8 wks thereafter at baseline, 8 wks, 20 wks, and 68 wks. Interventions G1: Clinical management Only G2: CT plus Clinical Management Medications allowed Continued on current medications with dose adjustments allowed Strategy Augmention Parameters Psychotherapy:; - Type of therapy: Cognitive Therapy; - Method: Individual; - Number of sessions/week: 1.25/wk; - Total number of sessions: 16 | TRD definition; - residual symptoms reaching at least 8 on the 17-item Hamilton Depression Rating Scale (HDRS)18 and 9 on the Beck Depression Inventory (BDI) and taking a tricyclic antidepressant, serotonin reuptake inhibitor, atypical antidepressant, or monoamine oxidase inhibitor for at least the previous 8 weeks, with 4 or more weeks at a daily dose at least equivalent to 125 mg of amitriptyline,; - Residual symptoms had lasted 2 to 18 months.; - Failure required to be in the current episode; Tier 2 Inclusion criteria; - Unipolar depression,; - aged 21 to 65 years,; - satisfying DSM-III-R17 criteria for major depression within last 18 months but not in last 2 months, and; - Had to be taking a tricyclic antidepressant, serotonin reuptake inhibitor, atypical antidepressant, or monoamine oxidase inhibitor for at least previous 8 weeks, with 4 or more weeks at a daily dose at least equivalent to 125 mg of amitriptyline, and higher levels unless there were definite current adverse effects or patient refusal to increase dose.; Exclusion criteria; - A history of bipolar disorder, cyclothymia, schizoaffective disorder, definite; - Intervention or alcohol dependence, persistent antisocial behavior or repeated self-harm,; - DSM-III-R dysthymia with onset before age 20 years,; - borderline personality, learning disability (estimated IQ,70),; - organic brain damage,; - any other primary Axis I disorder at time of index illness.; - Also excluded were patients currently receiving formal psychotherapy or those who had previously received CT for more than 5 sessions | Treatment Failure Mean failed trials G1: NR G2: NR Polarity, % Unipolar 100% 100% Age, mean yrs G1: 43.2 (11.2) G2: 43.5 (9.8) Sex, % females G1: 53% G2: 46% HAM-D 17 Baseline n G1: 78 G2: 80 Baseline score, mean (SD) G1: 12.2 (2.9) G2: 12.1 (2.7) BDI Baseline score, mean (SD) G1: 22.3 (8.0) G2: 21.9 (7.7) | HAM-D 17 G1: Clinical Management only G2: CT plus Clinical Management Endpoint score, mean (SD) At week 20 G1: 9.40 (5.2) G2 (5.2) Follow-up at 44 weeks G1: 8.7 (5.3) G2: 7.6 (4.7) Follow-up at 68 weeks G1: 7.2 (4.7) G2: 7.2 (5.3) Change, mean (SD) At week 20 G1: -2.8 G2: -3.4 P = NS Follow-up at 44 weeks G1: - 3.0 G2: -4.5 Follow-up at 68 weeks G1: -5.0 G2: -4.9 Responders, n NR Remitters, n (%) HAM-D<8 At week 20 G1: 10 (13) G2: 19 (24) Hazard Ratio for remission from intention to treat analysis: 2.42 (95% CI, (1.08, 5.45)) BDI Endpoint score, mean (SD) At 20 weeks G1: 16.1 (10.0), G2: 13.8 (9.6), Follow-up at 44 weeks G1: 17.3 (11.6) G2: 12.3 (9.3) Follow-up at 68 weeks G1: 14.3 (10.9) G2: 13.5 (11.7) Change, mean (SD) At week 20 G1: -6.24 G2: -8.44 Responders, n NR Remitters, n BDI <9 At week 20 G1: 10 (13%) G2: 19 (24.4%) Relapse n(%): At week 20: G1: 18 (23) G2: 10 (13) At week 44 G1: 40 (51) G2: 24 (30) At week 68 G1: 47 (60) G2: 29 (36) Hazard ratio for relapse = 0.54 (0.32-0.93) in favor of CT Actuarial Cumulative relapse rates at all time points for group 1: Awk20 = 18%, FUwk44 = 40%, FUwk68 = 47%; Actuarial Cumulative relapse rates at all time points for group 2: Awk20 = 10%, FUwk44 = 24%, FUwk68 = 29%;adjusted hazard ratio for relapse = 0.51, 95% CI, (0.32, 0.93). Over 17 months relapse rate was reduced from 47% among those who continued to be treated with antidepressants without CT to 29% among those who also received CT. #2219: Relapse was defined as: (1) meeting DSM-III criteria for major depressive disorder for a minimum of 1 month, and meeting severity criteria for major depression and score 17 or more on HAM-D 17 at 2 consecutive face-to-face assessments at least 1 week apart; (2) persistent residual symptoms during follow-up phase between 2 successive ratings 2 months apart, reaching a score on HAM-D 17 of at least 13 on both occasions and a level of distress or dysfunction for which the withholding of additional active treatment was no longer justified | Quality of Life NR Adverse Events NR Attrition Overall, % 20% did not adhere to protocol through to study end or relapse point At end of treatment, % G1: 4 G2: 14 At end of follow-up, % G1: 12 G2: 10 Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR Adherence/ compliance Adherence, n(%) G1: 61 (76%) G2: 66 subjects (85) [Control]

Evidence Table 27 KQ 4. General Tolerability: Tier 3 (ECT vs. rTMS—MDD)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year McLoughlin et al., 2007^7^ Eranti et al., 2007^8^ Knapp et al., 2008^9^ Country, setting UK, South London and Maudsley NHS Trust and Pembury Hospital inInvicta Mental Health Trust in Kent, 65.2% were inpatients Funding National Health Service Research and Development, National Coordinating Centre for Health Technology Assessment (NCCHTA) (98/11/04); by Guy's and St. Thomas's Charitable Foundation (R001126); and by a 2003 Ritter Independent Investigator Award from National Alliance for Research on Schizophrenia and Depression. Research Objective To assess clinical effectiveness of rTMS vs. ECT for treating major depressive episodes in patients referred for ECT Quality Rating Good | Study design RCT- pragmatic and single blinded (raters) Type of analysis m-ITT N 46 Duration Primary endpoint at 3 weeks for rTMS and at clinicians discretion for ECT, additional follow-up at 6 months Interventions G1: ECT G2: rTMS Medication Allowed Patients continued their usual medical care and stable psychotropic medications were allowed (i.e. SSRIS, TCAs, Venlafaxine, Mirtazapine, Lithium, Anticonvulsant mood stabilizers, Benzodiazepines, Antipsychotics, Zopiclone, L-Tryptophan) Strategy Augmentation Parameters rTMS; - Frequency (Hz): 10; - Motor threshold (%):110; - Number of trains: 20; - Length of train (seconds): 5; - Inter-train interval: 55; - Pulses per session: 1000; - Total number of sessions:15; ECT:; - % receiving bilateral: 82; - Intensity: 1.5 × ST for bilateral frontotemporal ECT and 2.5 × ST for right unilateral ECT; - Number of sessions (range, mean, SD): range = 2-10, mean = 6.3, SD = 2.5 | TRD definition; - All patients referred for ECT:; - No failure required; Tier 3 Inclusion criteria; - Right handed patients; - more than 18 years old; - refered for ECT due to major depressive episode; Exclusion criteria; - Inability to have rTMS because of metallic implants or foreign bodies; - History of seizures; - Substance misuse in previous 6 months; - Being medically unfit for general anesthesia or ECT:; - ECT or rTMS in previous 6 months,; - Dementia or other axis I diagnosis; - Inability or refusal to provide informed consent. | Treatment Failure Mean failed trials G1: 2.5 (1.4) G2: 2.4 (1.0) Polarity, % MDD G1: 91.67 G2: 90.91 Bipolar G1: 8.33% G2: 9.09 % Age, mean yrs G1: 63.6 G2: 68.3 Sex, % females G1: 67.7 G2: 72.7 Right handed, % Overall: 100% HAM-D 17 Baseline n G1: 22 G2: 24 Baseline score, mean (SD) G1: 24.8 (5.0) G2: 23.9 (7.0) BDI: Baseline score, mean (SD) G1: 36 (8.7) G2: 37.8 (10.5) | HAM-D 17 Analyzed n G1: 22 G2: 23 Endpoint score, mean (SD) End of treatment G1: 10.7 G2: 18.5 P = 0.002, effect size of 1.44 Follow-up at 6 months G1: NR G2: NR P = 0.93 Change, mean (SD) End of treatment G1: -14.1 G2: -5.4 P = 0.017 Responders, n End of treatment G1: 13 (59.1%) G2: 4 (17.4%) P = 0.005 Remitters, n HAM-D ≤ 8 End ot treatment G1: 13 (59.1%) G2: 4 (17.4%) P = 0.005 Follow-up at 6 months* G1: 6 (27.4%) G2: 2 (8.7%) *only 12 ECT remitters followed after End of txt BDI Endpoint score, mean (SD) NR P = 0.01 effect size=0.9 Change, mean (SD) NR Group × time, P = 0.25 Responders, n NR Remitters, n NR | Quality of Life SF-36 mental health component score Baseline n G1: 24 G2: 22 Baseline score, mean (SD) G1: 48.9 (12.6) G2: 42.7 (7.5) Other: QALYs Six month QALY gain, mean (SD) G1: 0.0300 (0.053) G2: 0.0297 (0.056) (QALYs were derived using SF-36 data). At six month follow-up, service use data were collected on 28 pts (10-ECT and 18-rTMS). Patients responded much better to ECT than to rTMS by the end of the allocated treatment course. The differential QALY gain of treatment with rTMS over ECT was 0.0003 (p = 0.987). This suggests that treatment by rTMS does not provide any additional gains in quality of life over ECT over a 6-month period. The lack of a statistically significant difference in QALY gain between the two groups may reflect lack of difference in HRSD scores between groups at 6 months. Adverse Events NR Neuropsychological or executive functioning Predefined CAMCOG Attention and orientation subscale (max = 17): ECT baseline 12.8 (3.2), end of treatment 13.9 (3.6), 6mos 13.9 (3.5) rTMS baseline 14.7 (3.0) end of treatment 13.5 (3.3) FU6mos 13.4 (3.8), P = 0.004 No significant differences for rest of CAMCOG subscales (verbal fluency, anterograde memory, and retrograde memory) MMSE Baseline score, mean (SD) G1: 24.3 (3.6) G2: 25.7 (3.9) Score at 6 months, mean (SD) G1: 25.4 (5.3) G2: 24.7 (4.8) Endpoint score, mean (SD) G1: 25.6 (3.9) G2: 24.4 (5.3) Change, mean (SD): G1: 1.3 G2: -1.3 P < 0.08 No significant differences on the Columbia ECT Subjective Side Effects Schedule for self-reported cognitive side effects. Attrition Overall to end of treatment 6/46, at 6 months 9/46 At end of treatment, % G1: 6/24 G2: 0 At end of follow-up, % NR Withdrawals due to efficacy, % G1: 5/24 G2: 0 Withdrawals due to adverse events, % 0 Adherence/ compliance NR
Author, Year O'Connor, 2003^64^ Country, setting United States, University Hospital, inpatient vs. outpatient population not clearly reported Funding NIH/NIMH and a NARSAD grant Research Objective Two procedures for treating major depressive disorder were compared with regard to their respective effects on mood and cognition Quality Rating Poor | Study design Observational Type of analysis Completers N 28 Duration; - Primary outcome at end of treatment (ECT applied for 2 to 4 weeks and rTMS a period of 2 weeks).; - Patients assessed for follow-up 2 weeks post txt; Medications allowed rTMS patients completed a washout of all psychotropic medications while ECT continued all medications Strategy Switch strategy for rTMS and augment or add-on strategy for ECT group Interventions G1: ECT G2: Parameters ECT; - % receiving bilateral:0; - Intensity: 2.5 times seizure threshold; - Number of sessions (range, mean, SD): 6-12,; rTMS; - Frequency (Hz):10; - Motor threshold (%): 90; - Number of trains: 20; - Length of train (seconds): 8; - Inter-train interval: 24; - Pulses per session: 1600; - Total number of sessions:5/wk over 2wks | TRD definition; - Patients referred for ECT; - AD failures not required; Tier 3 Inclusion criteria; - Met criteria for MDD; - HRSD > 18; Exclusion criteria; - Psychosis, acute suicidality, other current Axis I diagnoses in DSM IV; - known CNS pathology, pacemakers, electronic or metallic implants, severe cardiac pathology; - personal or first degree family history of a seizure disorder; - inability to give informed consent | Treatment Failure Mean failed trials NR Polarity, % 100% MDD Age, mean yrs G1: 48.4+/- 12.0 G2: 51.2 +/- 12.2 HAM-D Baseline n Completers G1: 14 G2: 14 Baseline score, mean (SD) G1: 38.07 (8.1) G2: 29.3 (4.9) P = 0.001 Wechsler Memory Scale-III (WMS-III)-Letter Number Sequencing subtest Baseline n G1: 14 G2: 14 Baseline score, mean (SD) G1: 10.92 (2.49) G2: 10.42 (3.0) | HAM-D Endpoint score, mean (SD) End of treatment G1: 15.3 (11.7) G2: 25.6 (7.7) Follow-up 2 weeks G1: 20.4 (9.5) G2: 24.8 (9.5) Change, mean (SD) End of treatment G1: -23.7 G2: -3.73 Group × time P < 0.01 Responders, n G1: NR G2: 0 Remitters, n G1: NR G2: 100% Other Validated measure Yes Wechsler Memory Scale-III (WMS-III)-Letter Number Sequencing subtest Endpoint score, mean (SD) G1: 9.23 (1.83) G2: 10.71 (3.83) Change, mean (SD) At two weeks ECT scores on LN based on completers per protocol (n=13). ECT pts did not demonstrate a significant change in LN performance compared directly with2 week follow-up results (P > 0.05) No significant interaction between treatment sessions and groups with respect to LN (P > 0.05) | Quality of Life Adverse Events NR Neuropsychological or executive functioning Rey Auditory Verbal Learning Test-RAVLT (15 item word list to test new learning) Baseline n G1: 14 G2: 14 Baseline score, mean (SD) G1: 43.78 (11.07) G2: 43.71 (12.09) Endpoint score, mean (SD) G1: 29.14 (7.93) G2: 43.00 (10.00) Change, mean (SD) G1: 46.92 (10.80)/ Difference between baseline acquisition and performance on acquisition task during 2-wk f/u session was not significant: P > 0.05 G2: 44.07 (10.43) RAVLT, Acquisition, mean (SD) Baseline: ECT 43.78 (11.07) vs. rTMS 43.71 (12.09). End of treatment: ECT 29.14 (7.93) vs. rTMS 43.00 (10.09) P < 0.01. Two weeks later: ECT 46.92 (10.80) vs. rTMS 44.07 (10.43) P > 0.05. RAVLT, Retention,(15-item word list after a 20-minute delay interval), mean (SD) Baseline ECT 8.07 (4.49) words vs. rTMS 9.76 (3.08) End of treatment ECT 2.14 ( 1.99) vs. rTMS 8.23 (2.80) Two weeks later, ECT 8.92 (4.14) vs. rTMS 8.31 (4.07). Transient News Events Test (TNET-measure of retrograde memory) Baseline n G1: 14 G2: 14 Baseline score, mean (SD) G1: 64.30 (19.40) G2: 55.62 (18.12) Endpoint score, mean (SD) G1: 39.10 (13,.21) G2: 57.81 (18.33) Change, mean (SD) G1: 59.20 (20.67) G2: 61.54 (19.12) Other Main-effect-of-group (P > 0.05). There was evidence of a significant interaction b/t txt grp and txt session: P < 0.001. Cognitive function/memory impairment reported as primary outcome measures. MMSE NR Attrition Overall, % No attrition At end of treatment, % NR At end of follow-up, % NR Withdrawals due to efficacy, % 0 Withdrawals due to adverse events, % 0 Adherence/ compliance NR

Evidence Table 28 KQ 4. General Tolerability: Tier 3 (rTMS vs. sham—MDD/Bipolar)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year George et al., 1997^35^ Country, setting USA, outpatient setting Funding NARSAD, Ted and Vada Stlanley Foundation Research Objective To test hypothesis: daily left prefrontal rTMS has antidepressant effects Quality Rating Fair | Study design RCT, crossover Type of analysis ITT N 12 Duration 4 wk (2 wk intervention, 2 wk. follow-up) Primary outcome: Change in HAM-D after 2wks active txt Interventions G1: rTMS G2: sham stimulation Medications Allowed ADs tapered for 9, 3 partial responders continued their medication Strategy Mixed-within group differences Parameters rTMS; - Frequency (Hz):20; - Motor threshold (%): 80; - Number of trains: 20; - Length of train (seconds): 2; - Inter-train interval: NR; - Pulses per session: 800; - Total number of sessions: 5/wk for a total of 20 per patient; Sham:; - Same as above but angled at 45 degrees from skull | TRD definition; - Implied TRD, all patients had completed 1 or more medication trials but were depressed at study entry; - Not required or not specified to be in current episode; Tier 3 Inclusion criteria; - DSM-IV criteria for current MDD; - right-handed; Exclusion criteria; - Pts w abnormalities on general & neurological exam, urine drug screen, HIV test, MRI scan of head),; - Pacemakers; - H/O seizures; - H/O major head trauma | Treatment Failure Number of previous AD medications Overall: 13.4 Polarity, % Unipolar Overall: 91.7 Bipolar II Overall: 8.3 Age, mean yrs Overall: 41.8 (12.4) Sex, % females Overall: 91.7 Right handed, % Overall: 100 HAM-D 21 Baseline n G1: 12 G2: 12 Baseline score, mean (SD) Overall: 28.5 (4.2) | HAM-D 21 G1: rTMS G2: sham stimulation Change, mean (SD) At 2 weeks G1: -5.25 G2: +3.33 P < 0.03 | Quality of Life NR Adverse Events Headache, % G1: 4/12 G2: NR Suicidality, % G1: 0 G2: Sham: 1/12 Seizures: None Unexpected side effects: None Headaches NR by active v. sham Memory or Attention: None Attrition Overall: 0 Adherence/ compliance N
Author, Year West, 1981^40^ Country, setting UK, Hospital, inpatient Funding NR Research Objective The therapeutic effect of simulated and real bilateral electric convulsion therapy Quality Rating KQ1 - Fair | Study design RCT Type of analysis Completers or per protocol (PP) N 25 (22 analyzed) Duration 3 weeks Interventions G1: ECT G2: Simulated ECT Medications Allowed 50 mg amitryptyline Strategy Combination Parameters The anaesthetic agent was Althesin (alphadolone) and the muscle relaxant suxamethonium. Electric convulsion therapy was administered from a Transycon machine using 40 joules with double-sided unrectified waveform and bilateral anterior temporal placement of the electrodes. | TRD definition; - Referred for ECT; Tier 3 Inclusion criteria; - Primary depressive illness; Exclusion criteria; - NR | Subgroups NR Baseline n G1: 13 G2: 12 Treatment Failure NR Polarity, % NR Patient Characteristics Age, mean yrs G1: 52.0 G2: 53.3 Sex, % females G1: 45 G2: 36 Race, % white NR Not Specified, % NR Right handed, % NR Groups similar at baseline Yes HAM-D 17 Baseline score, mean (SD) BDI Baseline score, mean (SD) G1: 26.6 (SEM 2.8) G2: 24.1 (3.5) | N Analyzed G1: 11 G2: 11 BDI Yes G1: ECT G2: Simulated ECT Endpoint score, mean (SD) G1: 10.8 (SEM 2.6) G2: 22.2 (3.8) P < 0.002 Change, mean (SD) G1: -15.8 G2: -1.9 Responders, n NR Remitters, n NR Other | Quality of Life No Adverse Events NR Neuropsychological or executive functioning No Measures, Results None reported Predefined NA - No AE data reported Adequate information NA - No AE data reported Attrition Overall, % 12% At end of treatment, % G1: 15.4 G2: 8.3 At end of followup, % NR Withdrawals due to efficacy, % G1: 7.7 G2: 8.3 Withdrawals due to adverse events, % NR Other Adherence/ compliance None reported

Evidence Table 29 KQ 4. Adherence: Tier 1 (ECT vs . rTMS—MDD only)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Rosa et al., 2006^2^ Country, setting Brazil, university clinic, inpatients and outpatients included Funding Not reported Research Objective To Compare efficacy and side effects associated with rTMS and ECT in an adult population with TRD Quality Rating Fair | Study design RCT Type of analysis Included completers analysis & ITT (LOCF), ITT is reported in abstraction N 42 Duration Active txt 2-4wks (rTMS pts not responding after 2 wks switched over to ECT), Primary Outcome: HAM-D response at 4wk Interventions G1: ECT G2: rTMS Medications allowed ADs, antipsychotics, mood stabilizers were discontinued while anti-anxiety meds were allowed/initiated as needed Strategy Switch Parameters rTMS:; - Frequency (Hz):10; - Motor threshold (%): 100; - Number of trains: 25; - Length of train (seconds): 10; - Inter-train interval: 20; - Pulses per session: 2500; - Total number of sessions: 20 over 4 wks; ECT:; - % receiving bilateral: NR; - Intensity: 4.5 times threshold; - Number of sessions (range, mean, SD): 10 (1.5) | TRD definition; - A lack of response to at 2+ antidepressants of different classes used for at least 4 wk with adequate dosages, with augmentation (with lithium or thyroid hormone for at least 1 trial); - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - Age 18-65; - unipolar depressive disorder (Ham-D >=22) w/o psychotic symptoms; Exclusion criteria; - History of epilepsy, neurosurgery with presence of metal clips, other neurological or psychiatric disease; - Use of cardiac pacemaker; - Pregnancy | Treatment Failure Previous treatment, not specified, % Overall:100% Polarity, % Unipolar Overal: 100% Age, mean yrs G1: 46.0 G2: 41.8 Sex, % females G1: 46.7 G2: 60.0 Race, % white G1: 80.0 G2: 90.0 HAM-D 17 Baseline n G1: 20 G2: 22 Baseline score, mean (SD) G1: 32.1 (5.0) [based on completers N = 15] G2: 30.1 (4.7) [N = 20] CGI Baseline n G1: 20 (N analyzed =15) G2: 22 (N analyzed =20) Baseline score, mean (SD) G1: 4.7 (0.8) G2: 4.3 (0.8) | HAM-D 17 Endpoint score, mean (SD) NR (graph only) Change, mean (SD) NR (graph only) P = 0.86 Responders, n (%) G1: 6 (20) G2: 10 (45) P = 0.35 Remitters, n (%) Ham-D17 <= 7 G1: 3 (15) G2: 2 (9) P = 0.65 Instrument CGI Endpoint score, mean (SD) 2wk G1: 4.0 (1.0) G2: 3.7 (1.1) 4wk G1: 3.2 (1.5) G2: 3.1 (1.3) Change, mean (SD) NR, P = 0.672 | Quality of Life NR Adverse Events Overall, % NR Suicidality, % G1: 10.0 G2: 9.1 rTMS: 2 pts developed new psychological symptoms (i.e. 1 = dissociative state, 1 = hypomanic symptoms) and were removed from study Neuropsychological or executive functioning NS differences between groups on all neuropsychological tests following wk2 & wk4. (Weschler Adult Intelligence Scale - R subtests (Vocabulary, Cube), Wechsler Memory Scale subtest (Digit Span), Rivermead Behavioral Memory Test) MMSE NR Other Attrition Overall, % 16.7 At end of treatment, % G1: 15.0* G2: 9.1* *Prior to completing txt (txt end date differed by pt) At end of follow-up, % G1: 25.0 G2: 9.1 Withdrawals due to efficacy, % G1: NR G2: 0.0 Withdrawals due to adverse events, % G1: NR G2: 9.1 Other For ECT, 3 were removed by their treating clinician w/o explanation or evaluation of efficacy Adherence/ compliance NR
Author, Year Schulze-Rauschenbach et al., 2005^63^ Country, setting Germany, Psychiatric University Hospital, inpatients Funding NR Research Objective To compare neurocognitive effects of unilateral ECT and rTMS using a control Quality Rating Fair | Study design Observational Type of analysis Observational study of patients completing txt N 30 Duration Not clear- testing took place 8.8 days on average afterlast treatment Estimated duration from mean number of txt – ECT 5 weeks and rTMS 3-5 weeks. Interventions Control G1: ECT G2: rTMS Medications Allowed Antidepressants, low-potency neuroleptics and non-benzodiazepine hypnotics were allowed in both groups. No med changes allowed during study Parameters ECT:; - % receiving bilateral: 0; - Intensity: 2.0-2.5 times seizure threshold; - Number of sessions (range, mean, SD): 9.9 (2.7); rTMS; - Frequency (Hz): 10; - Motor threshold (%): 100; - Number of trains: 20-30; - Length of train (seconds): 2; - Inter-train interval: 5; - Pulses per session:; - Total number of sessions: 2-3/wk; Strategy Augment or add-on | TRD definition; - Unsuccessful treatment response to at least two different types of antidepressants, each given in a sufficient dosage range for at least 4 weeks; - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - Consecutively admitted patients with DSM–IV diagnosis of MDD; - Age over 18 years; Exclusion criteria; - Previous treatment with ECT or rTMS; - Additional Axis I diagnosis | Treatment Failure Mean failed trials NR Polarity, % Unipolar 100% MDD Age, mean yrs G1: 46.7 G2: 47.7 Sex, % females G1: 50 G2: 44 HAM-D 17 Baseline n G1: 14 G2: 16 Baseline score, mean (SD) G1: 22.4 (3.1) G2: 21.3 (3.5) BDI Baseline n G1: 14 G2: 16 SSMQ Baseline n G1: 14 G2: 16 Baseline score, mean (SD) G1: -20.7 (19.0) G2: -16.8 (16.9) | HAM-D 17 Endpoint score, mean (SD) G1: 14.5 (5.7) G2: 13.0 (4.9) Change, mean (SD) G1: -7.9 G2: -8.3 Group × time, P = NS Responders, n G1: 6 (46%) G2: 7 (44%) P = 0.90 BDI Change, mean (SD) G1: 7.6 G2: 6.4Group × time, P = NS SSMQ Endpoint score, mean (SD) G1: -15.2 (25.2) G2: 3.8 (11.8) Change, mean (SD) G1: 5.5 G2: 20.6 | Quality of Life NR Adverse Events One patient in ECT group withdrew due to severe orientation and memory problems following two treatments; data not included. Neuropsychological or executive functioning Test scores ECT Pre / Post vs. rTMS Pre / Post Post; P = Post Ect vs. Post rTMS Learning and anterograde memory AVLT Immediate recall (trials 1-5); P = NS Recall after interference (trial 5 minus trial 6) 2.8 (2.2) / 3.9 (1.9) vs. 3.2 (1.9) / 1.8 (2.0); P < 0.01 Recall after delay (trial 5 minus trial 7) 2.4 (1.8) / 4.2 (1.6) vs. 3.2 (1.6) / 2.4 (2.0); P < 0.05 Recognition hits; P = NS and Recognition false alarms; P = NS MPT Recall trial; P = NS and Delayed recall; P = NS Retrograde memory Retrograde AVLT Recall; P = NS and Recognition hits; P = NS Recognition false alarms 5.0 (3.0) vs. 1.1 (1.1); P < 0.05 Four-card task Free recall 2.0 (1.4) / 0.4 (0.5) vs. 1.4 / (1.2); P < 0.05 Recognition; P = NS AMI Recall score; P = NS Subjective memory SSMQ -20.7 (19.0) / -15.2 (25.2) vs. -16.8 (16.9) / 3.8 (11.8); P < 0.05 Other cognitive functions MMSE; P = NS, TrailMakingTest A; P = NS, TrailMakingTest B; P = NS, Digit span (WAIS-R); P = NS, Letter-number span; P = NS, Word fluency (LPS); P = NS MMSE G1: ECT G2: rTMS G3: Control Baseline n G1: 14 G2: 16 G3: 15 Baseline score, mean (SD) G1: 27.9 (1.7) G2: 26.9 (3.4) G3: 29.1 (1.0) Endpoint score, mean (SD) G1: 28.3 (1.3) G2: 27.9 (3.0) G3: 29.2 (1.1) Change, mean (SD) G1: 0.4 G2: -1 G3: 0.01 Other P = NS Attrition Overall, % 3.3 At end of treatment, % G1: 7 G2: 0 At end of follow-up, % G1: NR G2: NR Withdrawals due to efficacy, % G1: 0 G2: 0 Withdrawals due to adverse events, % G1: 7 G2: 0 One person in ECT group withdrew because of severe orientation and memory problems after 2 ECT treatments; these data were not included in analysis Adherence/ compliance NR

Evidence Table 30 KQ 4. Adherence: Tier 1 (ECT vs. rTMS—MDD/Bipolar)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Grunhaus et al., 2000^62^ Country, setting Israel Sheba Medical Center, inpatients and outpatients Funding Established Investigator Award of NARSTAD Research Objective To compare rTMS to ECT and psychotic vs. non-psychotic Quality Rating Fair | Study design RCT Type of analysis ITT N 40 Duration Varied – ECT patients treated for average of 5 weeks, and rTMS pts treated for 4 weeks. Primary outcome measured at end of treatment Interventions Overall G1: ECT G2: rTMS Pts with psychosis G3: ECT: G4: rTMS Pts without psychosis G5: ECT G6: rTMS Medications allowed; - ECT allowed benzodiazepines, neuroleptics antidepressants and anticonvulsants in stable doses; - rTMS All psychiatric medications were discontinued only clonazepam (1–2 mg/day, given in twice-daily doses) was started in all patients to decrease anxiety, provide relief of severe insomnia, and have an additional protective element regarding seizures; Strategy Mixed-between group differences Parameters ECT:; - % receiving bilateral: 40 switched after non-response; - Intensity 2.5-fold seizure threshold; - Number of sessions -mean 9.6 sessions (range 7-14); rTMS; - Frequency (Hz):10; - Motor threshold (%):90; - Number of trains:NR; - Length of train (seconds):2 or 6; - Inter-train interval:NR; - Pulses per session: 400 or 1200; - Total number of sessions: 20 | TRD definition; - Pts referred for ECT:; - Only some patients treatment resistant (not defined). Treatment failure not required or not specified to be in current episode; Tier 3 Inclusion criteria; - age over 18; - DSM-IV diagnosis of MDD; - HAM-D17 ≥18; - no personal or first-degree relative history of seizure; - no medical, neurological, or neurosurgical disorder that would preclude administration of ECT or rTMS.; Exclusion criteria; - Additional Axis-1 diagnoses | Subgroups Patients with and with out Psychosis Treatment Failure Failed ≤1 trial, % G1: 50 G2: 25 Failed ≥2 trials, % G1: 50 G2: 75 Polarity, % 100% MDD Age, mean yrs G1: 63.6 (15.0) G2: 58.4 (15.7) Sex, % females G1: 70 G2: 60 HAM-D 17 Baseline n Overall G1: 20 G2: 20 Patients with Psychosis G3: 10 G4: 9 Patients without Psychosis G5: 10 G6: 11 Baseline score, mean (SD) G1: 28.4 (9.3) G2: 25.8 (6.1) G3: 31.5 (11.5) G4: 28.7 (5.6) G5: 25.2 (5.3) G6: 23.5 (5.6) | HAM-D 17 Endpoint score, mean (SD) At week 2 G1: 17.6 (7.4) G2: 19.3 (8.6) G3: 15.5 (7.6) G4: 23.4 (5.5) G5: 19.7 (7.0) G6: 15.8 (9.3) End of treatment G1: 11.2 (8.4) G2: 15.4 (7.5) G3: 8.4 (5.3) G4: 20.8 (5.0) G5: 13.9 (10.3) G6: 11.0 (6.2) Change, mean (SD) At week 2 G1: 10.8 G2: 6.5 G3: 16.0 G4: 5.3 G5: 5.5 G6: 7.7 End of treatment G1: 17.2 G2: 10.4 Group × time, P = 0.09 G3: 23.1 G4: 7.9 Group × time, P = 0.005 G5: 11.3 G6: 12.5 Group × time, P = NS Responders if the final HRSD had decreased to 50% or more from baseline and the final GAS < 60. Responders, n End of txt G1: 16 (80%) G2: 9 (45%) G3: 10 (100%) G4: 2 (22%) P ≤ 0.01 G5: 6 (60%) G6: 7 (63%) P = NS | Quality of Life Scale Pittsburg Sleep Quality Index Intervention G1: ECT G2: rTMs G3: NR G4: ECT Psychotic vs none G5: rTMS Psychotic vs none Baseline n G1: 20 G2: 20 G3: NR G4: 10 vs. 10 G5: 9 vs. 11 Baseline score, mean (SD) G1: 12.5 (4.4) G2: 11.7 (5.7) G3: NR G4: 12.1 (5.5) vs 12.9 (3.1) G5: 14.1 (4.9) vs 9.7 (5.8) Endpoint score, mean (SD) G1: Awk2 8.8 (4.5) / endpoint 6.8 (3.5) G2: Awk2 10.1 (3.7) / endpoint 10.5 (3.9) G3: NR G4: Awk2 8.0 (4.5) / endpoint 5.8 (2.1) vs G5: Awk2 12.2 (2.8) / endpoint 12.3 (3.6) vs. Awk2 8.4 (3.5) / endpoint 9.1 (3.8) Change, mean (SD) G1: Awk2 3.7 / endpoint 5.7 G2: Awk2 1.6 / endpoint 1.2 G3: G4: Awk2 4.1 / endpoint 6.3 vs Awk2 4.9 / endpoint 7.1 G5: Awk2 11.9 / endpoint 1.8 vs. Awk2 1.3 / endpoint 0.6 Other Overall Group F 1.8 (df 1,36) P = NS Time F 12.5 (df 2,72) P = 0.000 Interaction F 4.6 (df 2,2) P = 0.010 Non-psychotic Group F 0.5 (df 1,18) P = NS Time F 4.4 (df 2,36) P = 0.020 Interaction F 2.3 (df 2,2) P = NS Psychotic Group F 9.8 (df 1,16) P = 0.006 Quality of Life Overall Group F 1.8 (df 1,36) P = NS Time F 12.5 (df 2,72) P = 0.000 Interaction F 4.6 (df 2,2) P = 0.010 Non-psychotic Group F 0.5 (df 1,18) P = NS Time F 4.4 (df 2,36) P = 0.020 Interaction F 2.3 (df 2,2) P = NS Psychotic Group F 9.8 (df 1,16) P = 0.006 Scale Global Assessment of Function Scale Intervention G1: ECT G2: rTMS G3: G4: ECT Psychotic vs none G5: rTMS Psychotic vs none Baseline n G1: 20 G2: 20 G3: G4: 10 vs. 10 G5: 9 vs. 11 Baseline score, mean (SD) G1: 31.0 (8.5) G2: 34.1 (11.7) G3: Intervention4: 29.0 (7.0) vs. 33.0 (9.8) G5: 28.9 (9.9) vs. 38.3 (11.8) Endpoint score, mean (SD) G1: Awk2 46.8 (17.2)/ endpoint 61.5 (21.5) G2: Awk2 44.5 (14.7)/ endpoint 51.0 (18.2) G3: G4: Awk2 50.6 (18.3)/ endpoint 65.5 (18.8) vs. Awk2 43.0 (16.0)/ endpoint 57.5 (24.2) G5: Awk2 36.1 (8.2)/ endpoint 39.4 (14.5.) vs. Awk2 51.4 (15.5)/ endpoint 60.5 Change, mean (SD) G1: Awk2 15.8 / endpoint 30.5 G2: Awk2 10.4 / endpoint 16.9 G3: G4: Awk2 21.6 / endpoint 36.5 vs. Awk2 10.0 / endpoint 24.5 G5: Awk2 7.2 / endpoint 10.5 vs. Awk2 13.1 / endpoint 22.2 Other Overall Group F 0.7 (df 1,38) P = NS Time F 40.8 (df 2,76) P = 0.000 Interaction F 3.4 (df 2,2) P = 0.040 Non-psychotic Group F 1.0 (df 1,19) P = NS Time F 19.8 (df 2,38) P = 0.000 Interaction F 0.3 (df 2,2) P = NS Psychotic Group F 8.2 (df 1,17) P = 0.01 Adverse Events NR 5 rTMS patients had mild headaches Neuropsychological or executive functioning Measures, Results MMS. (ECT baseline 25.9 (4.1), ECT end of treatment 24.5 (7.6); rTMS baseline 24.8 (4.1), rTMS end of treatment 26.3 (3.9), repeated measures ANOVA [group effect F(1,29) = 0.1, P = NS; time effect F(2,58) = 1.3, P = NS; interaction F(2,2) = 2.3, P = NS) analysis was also performed for psychotic–non-psychotic groups with similar results. Predefined No MMSE Baseline n G1: 20 G2: 20 Baseline score, mean (SD) G1: 25.9 (4.1) G2: 24.8 (4.1) Endpoint score, mean (SD) G1: 24.5 (7.6) G2: 26.3 (3.9) Change, mean (SD) G1: -1.4 G2: +1.5 Other ANOVA [group effect F(1,29) = 0.1, P = NS; time effect F(2,58) = 1.3, P = NS; interaction F(2,2) = 2.3, P = NS) analysis was also performed for psychotic–nonpsychotic groups with similar results. Adequate information Attrition Overall, % 0% At end of treatment, % 0 At end of follow-up, % 0 Withdrawals due to efficacy, % 0 Withdrawals due to adverse events, % 0 Adherence/ compliance Compliance All patients completed study

Evidence Table 31 KQ 4. Adherence: Tier 1 (rTMS vs. sham—MDD only)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Garcia-Toro et al., 2006^17^ Country, setting Spain, single center, all outpatients Funding Fundacio La Marato de TV3 Research Objective To assess the efficacy of high and low frequency rTMS and different locations of activation Quality Rating Fair | Study design RCT Type of analysis Cannot tell, all reported patients included in analysis N 30 Duration; - Primary outcome after 2 weeks of active treatment; - Follow-up: 2 weeks post treatment; Interventions G1: Sham G2: rTMS G3: rTMS + SPECT (focused on different regions of brain after examination with single photon emission computed tomography [SPECT] exam) Medications allowed All pts continued (failed) AD medication and other psychotropic meds Strategy Augmentation Parameters rTMS Low:; - Frequency (Hz):1; - Motor threshold (%): 110; - Number of trains: 30; - Length of train (seconds): 60; - Inter-train interval:; - Pulses per session: 1800; - Total number of sessions: 10 in 2 wks; High; - Frequency (Hz):20; - Motor threshold (%): 110; - Number of trains: 30; - Length of train (seconds): 2; - Inter-train interval: 20+5; - Pulses per session: 1200; - Total number of sessions: 10 in 2 wks; Sham; - Same but with coil angling 45 degrees away from scalp | TRD definition; - Failed 2+ txt trials at 4+ weeks; - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - At least 18 yrs old, MDD, unipolar; Exclusion criteria; - Contraindications for rTMS and high suicide risk | Subgroups None Treatment Failure Mean failed trials NR Polarity, % Unipolar 100% Age, mean yrs G1: 47.2 G2: 48.5 G3: 51.1 Sex, % females G1: 70 G2: 40 G3: 40 Race, % white NR Right handed, % G1: 90% G2: 100% G3: 100% HAM-D 21 Baseline n G1: 10 G2: 10 G3: 10 Baseline score, mean (SD) G1: 25.10 (7.28) G2: 27.30 (4.97) G3: 25.00 (4.14) CGI-S Baseline n G1: 10 G2: 10 G3: 10 Baseline score, mean (SD) G1: 4.7 (0.82) G2: 4.8 (1.0) G3: 4.8 (0.63) | HAM-D 21 Endpoint score, mean (SD) At week 1 G1: 23.6 (7.04) G2: 24.1 (7.91) G3: 21.6 (3.10) At week 2 G1: 23.6 (7.79) G2: 20.10 (8.18) G3: 18.10 (6.15) Follow-up 2 weeks post treatment G1: 23.67 (5.55) G2: 20.88 (7.26) G3: 16.9 (7.0) Change, mean (% change) At 1 week G1: -1.5 (-5.9%) G2: -3.2 (-13.27%) G3: -3.4 (-13.6%) At 2 weeks G1: -1.5 (-5.9%) G2: -7.2 (-26.37%) G3: -6.9 (-27.6%) G1: vs. G2+G3 (mean = 7.05), P = 0.048 Follow-up at week 4 G1: -1.43 (-5.6%) G2: -6.42 (-23.51%) G3: -8.1 (-32.4%) G1: vs. G2+G3, P = 0.121 Responders, n (%) G1: 0 (0) G2: 2 (20) G3: 2 (20) P = NR CGI-S Endpoint score, mean (SD) At 2 weeks G1: 4.6 (0.97 G2: 3.8 (1.48) G3: 3.9 (0.99) 2 week follow-up G1: 4.75 (1.16) G2: 4.00 (1.15) G3: 3.7 (1.57) | Quality of Life NR Adverse Events NR Attrition Overall, % at 2 weeks 0%, during two week follow-up 3 patents withdrew due to changes in pharmacotherapy At end of treatment, % G1: 0 G2: 0 G3: 0 At end of follow-up, % NR Does not report which group 3 patients came from Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR rTMS+SPECT received active rTMS that was focused on different regions ofbrain after examination with single photon emission computed tomography (20-Hz rTMS to an area of relatively low activity and 1-Hz rTMS to an area showing relatively high activate Adherence/ compliance Compliance all patients completed active 2 week treatment
Author, Year Avery et al., 2006^10^ Country, setting USA, Single center, University department of psychiatry, outpatient Funding NIMH Research Objective To test hypothesis that patients receiving active TMS would show a greater antidepressant response rate than those receiving sham stimulation Quality Rating Good Fair for KQ2 and subgroups11 (small number of people followed for relapse; used a single measure and did not account for additional medical conditions) | Study design RCT Type of analysis ITT N 68 Duration 4 weeks (15 sessions) of txt, primary assessment 1 week after completion of txts. Responders were evaluated for relapse 2 wks after primary endpoint Interventions G1: High-left TMS G2: Sham Medications Allowed; - Pts encouraged, although not required, to discontinue current antidepressant medication, sedatives, or benzodiazepines; (continuing AD medication G1: 31% vs. G2: 27%; continuing benzodiazapines G1: 26% vs. G2: 24%); - Those stopping medications had to be medication-free for at least 2 weeks; - All responders given AD post rTMS treatment (active or sham); Strategy Mixed-within group differences Parameters rTMS; - Frequency (Hz):10; - Motor threshold (%): 110; - Number of trains: 32; - Length of train (seconds): 5; - Inter-train interval: 25-30; - Pulses per session: 1600; - Total number of sessions: 15 in 4 wks; Sham; - Identical stimulation parameters; - Lateral edgeof coil rotated 90° away from scalp | TRD definition; - Failed to respond to or unable to tolerate at least 2+ adequate AD trials (defined by score ≥3 on ATHF); - Failures not required to be in current episode; Tier 1 Inclusion criteria; - TRD; - 21 to 65 years old; - DSM-IV criteria for current major depressive disorder (MDD); - HAM-D 17 ≥ 17 and a decrease of no more than 20% between screening and 1st txt day; Exclusion criteria; - Previous TMS exposure; - bipolar disorder,; - previous failure of nine or more bitemporal ECT treatments; - current major depressive episode longer than 5 years; - history of substance abuse or dependence with inpast 2 years,; - antisocial or borderline personality disorder,; - active suicidal ideation; - current symptoms of psychosis,; - Hx of seizure disorder,; - Hx of closed head injury with loss of consciousness or prior brain surgery; - any other major psychiatric or medical comorbidity | Subgroups Pain, subgroup analysis presented in Avery et al, 2007^11^ Baseline n G1: 35 G2: 33 Treatment Failure Current episode failures, mean (SD) G1: 1.46 (0.78) G2: 1.48 (0.67) Mean failed trials (SD) G1: 3.2 (2.44) G2: 3.3 (1.72) Polarity, % Unipolar 100 Age, mean yrs G1: 44.3 G2: 44.2 Sex, % females G1: 60 G2: 52 Race, % white NR Right handed, % NR Groups similar at baseline Yes HAM-D 17 Baseline score, mean (SD) G1: 23.5 (3.9) G2: 23.5 (2.9) BDI Baseline score, mean (SD) G1: 28.1 (8.7) G2: 28.4 (8.0) | HAM-D 17 Endpoint score, mean (SD) G1: 15.7 G2: 19.8 Change, mean (SD) G1: -7.8 (7.8) G2: -3.7 (6.3) Group × time P = 0.002 Responders, n G1: 11 (31.4%) G2: 2 (6.1%) P = 0.008 Remitters, n HAM-D21 < 10 G1: 7 (20.0%) G2: 1 (3.0%) P = 0.033 No Relapse (at 6mos), N G1: 5 G2: Unknown (1 relapsed, 1 loss to follow after 3 mos of without relapse) BDI Change, mean (SD) G1: 11.3 (12.8) G2: 4.8 (8.5) Random Regression analyses revealed significant group by time interaction (P = 0.003) | Quality of Life NR Adverse Events Overall, % NR Site pain first session sham none (0/33) vs. TMS group, 41% (14/35)15th session sham 3% (1/30) vs. TMS 33% (11/33). The discomfort pain scale ratings (0-4) decreased inTMS group in subsequent treatment sessions, decreasing from a mean of 1.89 ( 1.02) at session 1 to 1.11 ( 1.03) at session 15 (t = 4.24, P < 0.001). Changes from baseline in128 individual SAFTEE scores -emerging symptoms were analyzed by chi-square analyses at visits 5, 10, 15, and 16 with a Bonferroni correction, there were no significant differences between TMS and sham in any ofemerging symptoms. (Data = NR) Neuropsychological or executive functioning No sig differences in GOAT, RAVLT, WAIS-R, COWAT, and SAFTEE; SUBGROUP ANALYSIS^11^: At 15th session pain TMS 33% vs, sham 3% (P < 0.05) no statistically significant (P > 0.05) time by treatment group interactions for any of neuropsychological test measures.models were refit withoutinteraction term, there was no significant treatment group main effect (P > 0.05) evident for any ofneuropsychological tests, indicatinggroups had similar levels of neuropsychological performance collapsed over time. Several measures showed significant main effects of time, that is, collapsed over groups, there was significant improvement in individual neuropsychological test performances for both groups. No confusion was associated with TMS treatments.GOAT assessments were well within normal range and ranged from 98 to 100. No significant (P > 0.05) differences between groups for any session. MMSE NR Attrition Overall, % 7.4% (5/68) At end of treatment, % NR At end of follow-up, % NR Withdrawals due to efficacy, % G1: 0 G2: 3.0 Withdrawals due to adverse events, % G1: 0 G2: NR Very unclear as to when patients discontinued Adherence/ compliance NR
Author, Year Bretlau, 2008^41^ Country, setting Denmark, setting NR, outpatients Funding Commercial source-please list name.supported by Medicon Valley Academy and an unrestricted research grant from H Lundbeck A/S Research Objective To do an interim analysis of a study on active rTMS combined with escitalopram versus sham TMS combined with escitalopram in the acute treatment Quality Rating Fair | Study design RCT Type of analysis Modified ITT (m-itt) N 49 Duration 12 weeks, but primary outcome was at 3 weeks after 15 rTMS sessions completed over a three week period. Escitalopram was administered during the entire trial at 20mg daily (10 mg daily for first wk of trial). Primary outcome (HAM-D6) was recorded at baseline, wk 2, 2k 3, 2k 5, 2k 8, and wk 12. Secondary outcome measures (HAM-D17 and MES) were recorded at the same intervals. Interventions B - Repetitive Transcranial Magnetic Stimulation (rTMS)E -Placebo G1: rTMS + escitalopram (n = 25) G2: sham TMS + escitalopram ( n= 24) G1: rTMS + escitalopram G2: sham TMS + escitalopram G1: rTMS + escitalopram** G2: sham TMS + escitalopram** Parameters Location = Left Dorslateral prefrontal cortex Frequency = 8 Hz Intensity = 90% motor threshold Per session = 20 trains of 8 seconds at 52-second intervals. Each txt session lasted 20 minutes. Number of sessions = 15 Strategy Augment or add-on strategy, for example the patients current treatment of an SSRI was added to or augmented with another treatment | TRD definition Required to be in current episode Yes Setting(s) Not clearly reported Inclusion criteria Aged 18 - 75 years; meet DSM-IV criteria for current major depressive disorder but not chronic subtype (i.e. current episode not > 24 months); failed to respond to at least one previous adequate (at least 6 weeks) antidepressant treatment during the current episode; subjects with heart disorders or diabetes were included if they were in a somatically stable phase Exclusion criteria Concurrent diagnosis of an organic brain disorder such as mental retardation, schizophrenia, or other psychotic disorders or personality disorders; potentail risk factors for escitalopram such as hypersensitivity to the Intervention, intake of monoamine-oxidase inhibitors of the irreversible type with the past 14 days, pregnancy or insufficient contraception in females of reproductive age; risk factors for TMS such as history of epilepsy, metal implants in the head or neck regions, pacemaker or other electronic implants, receiving antipsychotics; having major suicide ideation. | Subgroups No sub-group analysis Treatment Failure Failed 1 or more, % G1: 100 G2: 100 Failed 2 or more, % G1: NR G2: NR Current episode failures, mean G1: 2.8 (0.9) G2: 2.5 (0.9) Mean failed trials G1: NR G2: NR Polarity, % Unipolar G1: NR G2: NR Bipolar I G1: NR G2: NR Bipolar II G1: NR G2: NR Patient Characteristics Age, mean yrs G1: 53.1 G2: 57.8 Sex, % females G1: 68% G2: 57% Race, % white G1: NR G2: NR Not Specified, % G1: NR G2: NR Right handed, % G1: NR G2: NR Groups similar at baseline Yes Tier Tier 22A: 1+ failed, MDD | HAM-D Yes HAM-D 17 Other, please describe.HAM-D 6 G1: rTMS + escitalopram G2: sham TMS + escitalopram Baseline n G1: n @ baseline = 25; M-ITT = 23 G2: n@ baseline = 24; M-ITT = 22 Baseline score, mean (SD) G1: HAM-D 17 = 25.3 (3.0); HAM D 6 = 14.0 (1.0) G2: HAM-D 17 = 24.7 (3.2); HAM D 6 = 13.3 (1.5) Endpoint score, mean (SD) G1: HAM-D 17: Awk2 = 19.8 (5.1), Awk3 = 16.4 (4.5), FU wk 5 = 14.5 (5.2), FU wk8 = 12.4 (5.8), FU wk12 = 11.1 (6.7); HAM D 6 = Awk2 = 11.5 (2.6), Awk 3 = 10.0 (2.5), FU wk 5 = 8.9 (2.6), FU wk 8 = 7.9(3.1), FU wk 12 6.7 (4.1) G2: HAM-D 17: = A wk 2 = 22.3(4.5), A wk 3 = 19.1 (4.8), FU wk 5 = 16.3 (5.1), FU wk 8 = 15.3 (6.4), FU wk 12 = 13.5 (7.2); HAM D 6: Awk 2 = 12.5(2.3), A wk 3 = 11.4 (2.7), FU wk 5 = 10.0 (2.9), FU wk 8 = 8.9 (3.6) FU wk 12 = 8.1 (4.2) Change, mean (SD) G1: HAM-D 17 = 14.2 ; HAM D 6 = 7.3 G2: HAM-D 17 = 11.2; HAM D 6 = 5.2 Responders, n G1: NR G2: NR Remitters, n G1: NR G2: NR Other The effect size on the primary outcome measure (HAM-D 6) was greatest after two weeks of therapy (0.80 in favour of rTMS), but after 3 weeks of therapy, the effect size was 0.65 (still > 0.40). It remained above 0.40 at the 12 week endpoint (0.47). HAM-D17 Awk 2 Effect size (95% CI) and Mann-Whitney P = 0.83 (0.22-1.44), P = 0.02; HAM-D17 Awk 3 Effect size (95% CI) and Mann-Whitney P: 0.78 (0.18 - 1.39), P = 0.01; HAM-D17 FU wk 5 Effect size (95% CI) and Mann-Whitney P: 0.48(-0.12 - 1.07), P = 0.09; HAM-D17 FU wk 8 Effect size (95% CI) and Mann-Whitney P: 0.64 (0.04 - 1.24), P = 0.05; HAM-D17 FU wk 12 Effect size (95% CI) and Mann-Whitney P: 0.47 ( -0.11 - 1.07), P = 0.22; HAM-D6 Awk 2 Effect size (95% CI) and Mann-Whitney P: 0.73 (.018 -1.39), P = 0.05; HAM-D6 Awk 3 Effect size (95% CI) and Mann-Whitney P: 0.80 (0.20 - 1.42), P = 0.01; HAM-D6 FU wk 5 Effect size (95% CI) and Mann-Whitney P: 0.65 (0.09 -1.29), P = 0.02; HAM-D6 FU wk 8 Effect size (95% CI) and Mann-Whitney P:0.50 (-0.10 -1.09), P = 0.10; HAM-D6 FU wk 12 Effect size (95% CI) and Mann-Whitney P: 0.0.50 (-0.10 - 1.09), P = 0.09; BDI G1: rTMS + escitalopram* (See comments) G2: sham TMS + escitalopram Baseline n G1: n @ baseline = 25; M-ITT = 23 G2: n@ baseline = 24; M-ITT = 22 Baseline score, mean (SD) G1: 23.9 (2.4) G2: 23.0 (3.0) Endpoint score, mean (SD) G1: A wk 2 = 19.5 (4.4), A wk 3 = 16.5 (4.7), FU wk 5 = 14.2 (4.7), FU wk 8 = 12.8, FU wk 12 = 11.5 (6.8) G2: A wk 2 = 21.3 (4.1), A wk 3 = 19.2 (4.4), FU wk 5 = 16.4 (5.2), FU wk 8 = 15.4 (6.2), FU wk 12 = 13.6 (6.9) Change, mean (SD) G1: 12.4 G2: 9.4 Responders, n NR Remitters, n NR Other *Bech-Rafaelsen Melancholia scales (MES) reported NOT BDI MES Awk 2 Effect size (95% CI) and Mann-Whitney P = 0.73 (0.12 - 1.33), P = 0.03; Awk 3 Effect size (95% CI) and Mann-Whitney P: 0.84 (0.24 -1.46), P = 0.00; FU wk 5 Effect size (95% CI) and Mann-Whitney P: 0.64(0.02 -1.22), P = 0.03; FU wk 8 Effect size (95% CI) and Mann-Whitney P: 0.65 (0.04 - 1.24 ), P = 0.03; FU wk 12 Effect size (95% CI) and Mann-Whitney P: 0.46 ( -0.12 - 1.06), P = 0.12; MADRS NR IDS NR CGI-S NR CGI-I NR Instrument Major Depression Inventory (MDI) Baseline n G1: n @ baseline = 25; M-ITT = 23 G2: n@ baseline = 24; M-ITT = 22 Baseline score, mean (SD) G1: 33.5 (5.1) G2: 34.0 (5.6) Endpoint score, mean (SD) G1: A wk 2 = 23.8 (9.0), A wk 3 = 21.5 (9.8), FU wk 5 = 20.1 (9.0), FU wk 8 = 18.4 (10.0), FU wk 12 = 16.1 (10.7) G2: A wk 2 = 27.9 (10.6), A wk 3 = 26.6 (9.9), FU wk 5 = 23.7 (9.5), FU wk 8 = 21.5 (11.0), FU wk 12 = 19.6 (12.8) Change, mean (SD) G1: 17.4 G2: 14.4 MDI Awk 2 Effect size (95% CI) and Mann-Whitney P = 0.36 (-0.23 - 0.94), P = 0.18; Awk 3 Effect size (95% CI) and Mann-Whitney P:0.43 (-0.16 - 1.03), P = 0.29; FU wk 5 Effect size (95% CI) and Mann-Whitney P: 0.29 (-0.29 - 0.88), P =0.20; FU wk 8 Effect size (95% CI) and Mann-Whitney P: 0.22 (-0.36 - 0.81 ), P = 0.72; FU wk 12 Effect size (95% CI) and Mann-Whitney P: 0.23 ( -0.36 -0.81), P = 0.43; | Quality of Life NR Adverse Events Overall NR Amnesia, % G1: memory impairment: 3wk/ 12 wk mean: 0.00/0.00 G2: 0.13/0.00 Cardiovascular adverse events, % G1: palpatations: 3wk/ 12 wk mean: 0.23/0.14 G2: 0.30/0.12 Cognitive impairment, % G1: concentration difficulties 3wk/ 12 wk mean: 1.43/0.71 G2: 1.52/1.22 Headache, % G1: 3wk/ 12 wk mean: 0.18/0.10 G2: 0.43/0.06 Insomnia, % G1: reduced duration of sleep 3wk/ 12 wk mean: 0.45/0.24 G2: 0.91/0.39 Somnolence, % NR Suicidality, % NR Additional Comments **Adverse events are reported by the UKU side-effect scale and reported as mean and standard deviation** Sig differences (P <= 0.05) compared to active: at 3wks, with sham pts have higher reduction in sleep; at 12 wks, more sham pts have concentration difficulties Study utilized the UKU scale as listed before - Other adverse events inlcude: tension/inner unrest: Sham AK wk 3 = 1.48 (0.67)/ FU wk 12 = 0.89 (0.32); rTMS A wk 3 = 1.36 (0.49), FU wk 12 1.00 (0.63); Tremor: Sham AK wk 3 = 0.17 (0.39)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.14 (0.35), FU wk 12 0.05 (0.12); Akathisia: Sham AK wk 3 = 0.04 (0.21)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.05 (0.21), FU wk 12 0.00 (0.00); Nausea: Sham AK wk 3 = 0.35 (0.49)/ FU wk 12=0.17 (0.51); rTMS A wk 3 = 0.14 (0.35), FU wk 12 0.05 (0.22); Diarrhea: Sham AK wk 3 = 0.09 (0.29)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.14 (0.35), FU wk 12 0.10 (0.30); Diminished Sexual Desire: Sham AK wk 3 = 1.45 (0.74)/ FU wk 12 =0.94 (0.73); rTMS A wk 3 = 1.27 (0.94), FU wk 12 0.71(0.56); Dry Mouth: Sham AK wk 3 = 0.43 (0.56)/ FU wk 12 = 0.11 (0.32); rTMS A wk 3 = 0.27 (0.46), FU wk 12 0.14(0.36); Micturia: Sham AK wk 3 = 0.09 (0.29)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.05 (0.22), FU wk 12 0.00 (0.00); Neuropsychological or executive functioning No Measures, Results NR Predefined Yes MMSE No NR Baseline n NR Baseline score, mean (SD) NR Endpoint score, mean (SD) NR Change, mean (SD) NR Other Yes Study utilized the UKU scale as listed before - Other adverse events inlcude: tension/inner unrest: Sham AK wk 3 = 1.48 (0.67)/ FU wk 12 = 0.89 (0.32); rTMS A wk 3 = 1.36 (0.49), FU wk 12 1.00 (0.63); Tremor: Sham AK wk 3 = 0.17 (0.39)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.14 (0.35), FU wk 12 0.05 (0.12); Akathisia: Sham AK wk 3 = 0.04 (0.21)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.05 (0.21), FU wk 12 0.00 (0.00); Nausea: Sham AK wk 3 = 0.35 (0.49)/ FU wk 12 =0.17 (0.51); rTMS A wk 3 = 0.14 (0.35), FU wk 12 0.05 (0.22); Diarrhea: Sham AK wk 3 = 0.09 (0.29)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.14 (0.35), FU wk 12 0.10 (0.30); Diminished Sexual Desire: Sham AK wk 3 = 1.45 (0.74)/ FU wk 12 =0.94 (0.73); rTMS A wk = 1.27 (0.94), FU wk 12 0.71(0.56); Dry Mouth: Sham AK wk 3 = 0.43 (0.56)/ FU wk 12 = 0.11 (0.32); rTMS A wk 3 = 0.27 (0.46), FU wk 12 0.14(0.36); Micturia: Sham AK wk 3 = 0.09 (0.29)/ FU wk 12 = 0.00 (0.00); rTMS A wk 3 = 0.05 (0.22), FU wk 12 0.00 (0.00); Adequate information Yes Attrition Overall, % 3 RTMS patients did not complete protocol, and 1 sham patient did not complete (analysis used last observation carried forward). At 3 week outcome, all 45 patients in m-ITT were present. By end of study at 12 weeks, 6/49 (12%) had dropped out. At end of treatment, % G1: At end of rTMS (3 wks) = 0 G2: At end of Sham (3 wks) = 0 At end of follow-up, % G1: 21% G2: 4% Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR Adherence/ compliance NR
Author, Year Holtzheimer et al., 2004^19^ Country, setting USA, single center, outpatient/inpatient status not clearly stated Funding University of Washington Research Objective Initial hypotheses that rTMS would have greater antidepressant effects than sham stimulation and that rTMS would be safe and tolerable Quality Rating Fair | Study design RCT Type of analysis ITT N 15 Duration Primary endpoint following 2 weeks of treatment and follow-up 1 week after txt completed Interventions G1: rTMS G2: Sham Medications Allowed All pts discontinued (failed) AD medication Strategy Switch Parameters rTMS; - Frequency (Hz): 10; - Motor threshold (%): 110; - Number of trains:32; - Length of train (seconds): 5; - Inter-train interval: 30-60; - Pulses per session: 1600; - Total number of sessions: 10 over 2 wks; Sham rTMS; - Delivered in same anatomical location with identical stimulation parameters, but with lateral edge of coil rotated 45 degrees away from scalp | TRD definition; - Subjects must have failed at least two previous antidepressant trials due to lack of response to an adequate trial (defined by ATHF) or medication intolerance; - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - 21 to 65 years of age; - Right-handed; - Meet DSM-IV criteria for a major depressive episode due to MDD; - HAM-D17 ≥ 18; Exclusion criteria; - No other major psychiatric or medical comorbidity; - History of Bipolar Disorder; - Previous failure of ECT; - History of substance abuse or dependence; - Current symptoms of psychosis; - Pregnancy | Treatment Failure Failed 7 or more, % G1: 85.7 G2: 37.5 Polarity, % Unipolar 100% MDD Age, mean yrs G1: 40.4 G2: 45.4 Sex, % females G1: 57.1 G2: 42.9 Right handed, % G1: 100 G2: 100 HAM-D 17 Baseline n G1: 7 G2: 8 Baseline score, mean (SD) G1: 22.7 (5.3) G2: 20.8 (6.3) BDI Baseline score, mean (SD) G1: 29.6 (10.0) G2: 28.5 (10.6) | HAM-D 17 Endpoint score, mean (SD) At week 1 G1: 18.0 (1.2) G2:18.0 (2.7) At week 2 G1: 14.6 (3.2) G2: 15.3 (3.0) 1 week follow-up G1: 18.8 (2.5) G2: 17.6 (2.1) Change, mean (SD) At week 1 G1: 4.7 G2: 2.8 At week 2 G1: 8.1 G2: 5.5 1 week follow-up G1: 3.9 G2: 3.2 All endpoints, P = NS Responders, n (%) At week 1 G1: 0 G2: 0 At week 2 G1: 2 (28.6) G2: 1 (12.5) 1 week follow-up G1: 0 G2: 0 BDI Endpoint score, mean (SD) At week 1 G1: 27.5 (3.2) G2: 24.9 (2.7) At week 2 G1: 23.9 (2.6) G2: 22.4 (2.4) 1 week follow-up G1: 23.9 (1.6) G2: 26.4 (1.9) Change, mean (SD) At 2 weeks G1: 5.7 G2: 6.1 Change, mean (SD) 1 week follow-up G1: -5.7 G2: -2.1 Group × time (all points), P = NS | Quality of Life NR Adverse Events No major adverse events at any point in study. Some subjects experienced mild pain with active rTMS, but treatments were generally well tolerated. Neuropsychological or executive functioning Both groups performed equally well with exception of one measure of verbal memory, Trial 7 ofRey Auditory Verbal Learning Test, in which subjects that received rTMS performed slightly better (rTMS: mean score = 12.7 (2.1) vs.: sham mean score = 12.0 (2.3); P < 0.05). No acute changes in level of consciousness, orientation, or short-term memory associated with any rTMS or sham treatments sessions. MMSE NR There were no major adverse events at any point in study. Some subjects experienced mild pain with active rTMS, but treatments were generally well tolerated. Attrition Overall, % 0 during treatment. 3 (20%) before final assessment at week 3 At end of treatment, % 0 At end of follow-up, % G1: 28.6 G2: 12.5 Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR Other NR Adherence/ compliance Compliance All 15 subjects completed all 10 txt sessions

Evidence Table 32 KQ 4. Adherence: Tier 1 (rTMS vs. sham—MDD/Bipolar)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Boutros et al., 2002^13^ Country, setting US, Yale School of Medicine and VA-Connecticut, outpatient Funding VA Merit Award & K24 DA00520-01A1/DA/NIDA NIH HHS; 1 author employee of Pfizer Research Objective To provide additional data on effiacy and safety for rTMS as an augment strategy in TRD Quality Rating Fair | Study design RCT Type of analysis ITT N 21 Duration 2 weeks txt; follow-up with responders for up to 20 weeks post txt Interventions G1: rTMS G2: Sham Medications Allowed Pts allowed to continue all current psychotropic meds Strategy Augmentation, 3 pts in active and 1 in sham txt were not on any meds Parameters rTMS:; - Frequency (Hz):20; - Motor threshold (%): 80; - Number of trains: 20; - Length of train (seconds): 2; - Inter-train interval: 58; - Pulses per session: 800; - Total number of sessions: 10 over 10 weekdays; Sham:; - Coil angled 90 degrees to scalp; - 1 wing of figure 8 touching scalp | TRD definition; - 2+ failed trials of adequate dose and durations; - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - Major Depression; - HAM-D25 >= 20; Exclusion criteria; - Suicidality; - “Prominent” psychotic sympotms; - History of neurological disorders; - current drug abuse | Treatment Failure Mean failed trials NR Polarity, % Unipolar Overall: 100% Age, mean yrs G1: 49.5 G2: 52.0 Sex, % females G1: 25 G2: 10 Right handed, % G1: 90.9 G2: 88.9 HAM-D Baseline n G1: 12 G2: 9 Baseline score, mean (SD) G1: 34.4 (10.1) G2: 31.7 (4.9) | HAM-D Endpoint score, mean (SD) At 2 weeks G1: 29.0 G2: 28.11 Change, mean (SD) G1: -11.75 G2: -6.22 P = NS Responders, n Defined as 30% improvement on HAM-D G1: 7 G2: 2 Responders, n (%) Defined as 50% improvement on HAM-D G1: 3 G2: 2 Relapse Of 6 active treatment responders inluded in20-week follow-up (no continuing intervention), 4 relapsed. Of 1 sham responder included in thh 20-week follow-up, 1 relapsed. | Quality of Life NR Adverse Events Overall, % G1: (% of pts reporting AEs) 66.7 G2: 55.6 Cognitive impairment, % Difficulty concentrating (phase 1 only) G1: 25 G2: NR Headache, % “most frequent complaint” % NR Other:; - scalp tenderness at site of stimulation: 25%, 11.1%; - hearing problem: 8.3%, NR;; - diarrhea: 8.3%, NR; Attrition Overall, % 18.2% (4/22) At end of treatment, % G1: 8.3 (1/12) G2: 30.0 (3/10) At end of follow-up, % NR Withdrawals due to efficacy, %: NR Withdrawals due to adverse events, %: NR Adherence/ compliance NR
Author, Year Fitzgerald et al., 2006^14^ Country, setting Australia, single center Funding Australian National Health and Medical Research Council and by Constance and Stephen Lieber through a National Alliance for Research on Schizophrenia and Depression Lieber Young Investigator award (to Dr. Fitzgerald) Research Objective rTMS versus placebo for depression Quality Rating Good | Study design RCT Type of analysis ITT (LOCF) N 50 Duration 2 wks double blind with those with >20% decrease in MADRS to continue treatment for up to 6 wks with active or sham txt (LOCF for all pts); sham pts with inadequate response were allowed to enter open label txt. Primary outcome after 2 and 6 weeks of txt Interventions G1: rTMS G2: Sham Medications allowed; - Stable medications allowed; - SSRIs, SNRIs, Tricyclics ADs; - Mood stabilizers,; - Lithium,; - Anticonvulsants,; - Antipsychotic medication,; - Benzodiazepines; Strategy Augmentation, 23% not taking medication at study entry Parameters rTMS Low Right: Frequency (Hz):1; - Motor threshold (%): 110; - Number of trains: 3; - Length of train (seconds): 140; - Inter-train interval: 180; - Pulses per session: 420; Sequential High Left:; - Frequency (Hz): 10; - Motor threshold (%): 100; - Number of trains: 15; - Length of train (seconds): 5; - Inter-train interval: 25; - Pulses per session: 750; - Total number of sessions: 10 sessions/day, 5 days/wk; Sham:; - Coil angled at 45 degrees off head. Medial wing of coil was resting on scalp; - Stimulation parameters identical to those for active treatment (both sides) | TRD definition; - 2+ failed medications with txt duration ≥6 wks; - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - DSM-IV diagnosis of Major Depressive Episode; - MADRS ≥ 20; Exclusion criteria; - Significant medical illness; - Neurological disorders; - Other axis I psychiatric disorders | Treatment Failure Mean failed AD trials (lifetime) G1: 5.6 (3.1) G2: 6.2 (3.0) Polarity, % Unipolar G1: 84% G2: 84% Bipolar G1: 16% G2: 16% Age, mean yrs G1: 46.8 G2: 43.7 Sex, % females G1: 60 G2: 64 HAM-D 17 Baseline n G1: 25 G2: 25 Baseline score, mean (SD) G1: 22.5 (7.4) G2: 19.8 (4.4) BDI Baseline n G1: 25 G2: 25 Baseline score, mean (SD) G1: 29.2 (18.3) G2: 29.3 (9.9) MADRS Baseline n G1: 25 G2: 25 Baseline score, mean (SD) G1: 34.0 (5.9) G2: 34.1 (5.2) | HAM-D 17 Endpoint score, mean (SD) NR Change, % decrease (SD) G1: 45.2% (40.1) G2: 5.4% (23.1) P < 0.001 Change, mean G1: -10.17 G2: -1.07 Responders, n (%) At 6wks G1: 13 (52.0) G2: 2 (8.0) P = 0.001 Remitters, n At 6wks G1: 10 (40.0) G2: 0 (0) P = NR BDI Endpoint score, mean (SD) At week 2 G1: 18.3 (10.3) G2: 221.6 (13.7) At 4 weeks G1: 10.5 (8.3) G2: 21.0 (19.8) At 6 weeks G1: 9.2 (6.7) G2: NR Change, mean (SD) At week 2 G1: 10.9 G2: 7.7 At 4 weeks G1: 18.7 G2: 8.3 At 6 weeks G1: 20.0 G2: NR, P = 0.01 Responders, n NR Remitters, n NR MADRS Endpoint score, mean (SD) At week 2 G1: 26.2 (10.2) G2: 30.9 (8.2) At week 4 G1: 11.7 (7.1 G2: 34.5 (12.0) At week 6 G1: 8.9 (7.9) G2: NA Change, mean (SD) At week 2 G1: 7.8 G2: 3.2 At week 4 G1: 22.3 G2: 0.4 (increased) At week 6 G1: 25.1 G2: NA Group by time, P = 0.001 at all time points Responders, n At 6 weeks G1: 11 G2: 2 P < 0.05 Remitters, n MADRS < 10 At 6 weeks G1: 9 G2: 0 P = 0.005 At week 2 G1: 2 G2: 0 Follow-up at week 3 G1: 3 G2: 0 Follow-up at week 4 | Quality of Life GAF Baseline n G1: 25 G2: 25 Baseline score, mean (SD) G1: 48.8 (8.2) G2: 49.0 (4.9) Endpoint score, mean (SD) G1: 59.0 (16.5) G2: 50.1 (10.3) [P <0.05] Change, mean (SD) G1: 10.2 G2: 1.1 GAF Scale (t=2.0, df=40.2, P < 0.05) Adverse Events Headache, % G1: 20 G2: 8 Nausea 12% vs. 0, No seizures or manic episodes; Hopkins Verbal Learning Test performance decreased for both groups with no group by time interaction. Performance improved ondigit span backward test improved in rTMS only (group by time: P = 0.07). Controlled Oral Word Association test improved for both groups (time: P = 0.001). Nausea 12% vs. 0, No seizures or manic episodes; Neuropsychological or executive functioning Hopkins Verbal Learning Test Performance decreased for both groups with no group by time interaction Digit span backward Test Performance improved in rTMS only (group by time: P = 0.07). Controlled Oral Word Association Test Improved for both groups P = 0.001 MMSE NR Other Nausea 12% vs. 0 No seizures or manic episodes; Attrition Overall, % At 2 weeks: 6 At 3 weeks: 56 At 4 weeks: 70 At 5 weeks: 78 At 6 weeks: 78 After initial 2 weeks, patients that did not have a 10% reduction on a weekly assessment were withdrawn At end of treatment, % G1: 0 G2: 12 At end of follow-up, % G1: 56 G2: 100 Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR Adherence/ compliance NR
Author, Year Fitzgerald et al., 2003^15^ Country, setting Australia 2 general psychiatric services, outpatients Funding National Health and Medical Research Council and a grant fromStanley Medical Research Institute Research Objective To evaluate efficacy of HFL-TMS and LFR-TMS in treatment-resistant depression and compared with a sham-treated control group Quality Rating Good | Study design RCT Type of analysis ITT N 60 Tier 1 Duration Primary endpoint after 2 weeks of txt, after which pts with <20% reduction in MADRS could cross over to the other active txt. Follow-up assessment conducted at 2 weeks post txt. Interventions G1: High Frequency rTMS G2: Low Frequency rTMS G3: Sham Medications Allowed 46 patients continued (failed) AD medication while others were not on a med at study entry. Patients allowed mood stabilizers and antipsychotics Strategy Augmentation Parameters rTMS LowFrequency (Hz):1; - Motor threshold (%): 100; - Number of trains: 60; - Length of train (seconds): 5; - Inter-train interval:60; - Pulses per session: 300; - Total number of sessions: 10 sessions daily, 5 days/week; rTMS High; - Frequency (Hz):10; - Motor threshold (%): 100; - Number of trains: 20; - Length of train (seconds): 5; - Inter-train interval: 25; - Pulses per session: 1000; - Total number of sessions: 10 sessions daily, 5 days/week; Sham rTMS; - Coil angled 45 degrees offhead for 10 sessions daily, 5 days/week | TRD definition; - Failed a minimum of 2 courses of antidepressant medications (6+ weeks); Not required or not specified to be in current episode Inclusion criteria; - DSM-IV diagnosis of Major Depression (included bipolar depression); Exclusion criteria; - Significant medical illnesses, neurologic disorders, or other Axis I psychiatric disorders | Treatment Failure Mean failed trials Overall (SD) 5.68 (3.40) Polarity, % Bipolar I G1: 5 G2: 5 G3: 20 Age, mean yrs G1: 42.2 G2: 45.55 G3: 49.15 Sex, % females G1: 40 G2: 35 G3: 55 Right handed, % G1: 90 G2: 100 G3: 85 BDI Baseline n G1: 20 G2: 20 G3: 20 Baseline score, mean (SD) G1: 33.15 (12.12) G2: 35.05 (9.25) G3: 32.30 (9.10) MADRS Baseline n G1: 20 G2: 20 G3: 20 Baseline score, mean (SD) G1: 36.05 (7.55) G2: 37.70 (8.36) G3: 35.75 (8.14) | BDI Endpoint score, mean (SD) At 2 weeks G1: 26.7 (11.9) G2: 27.2 (10.8) G3: 29.0 (8.7) Change, mean (SD) At 2 weeks G1:- 6.4 G2: -7.8 G3: -2.3 P = 0.03 MADRS Endpoint score, mean (SD) At 2 weeks G1: 30.8 (7.8) G2: 32.2 (9.0) G3: 35.4 (7.5) Change, mean; % change, (SD) At 2 weeks G1: -5.25; 13.5 % (16.7%) G2: -5.5; 15.0% (14.1%) G3: -0.35; 0.76% (16.2%) P = 0.004 G1: vs. G3, G2 vs. G3, P < 0.005 Responders, n 20% ≤ decrease At 2 weeks G1: 8 (40) G2: 7 (35) G3: 2 (10) P = 0.07 Responders, n 50% ≤ decrease At 2 weeks G1: 0 G2: 1 (5) G3: 0 P = NR CGI Endpoint score, mean (SD) NR P =.01 | Quality of Life GAF Global Assessment of Functioning Baseline n G1: 20 G2: 20 G3: 20 Baseline score, mean (SD) G1: 43.00 (6.76) G2: 43.55 (9.94) G3: 42.75 (7.15) Endpoint score, mean (SD) At 2 weeks G1: 45.2 (7.1) G2: 46.3 (8.5) G3: 42.5 (6.8) Change, mean (SD) At 2 weeks G1: 2.2 G2: 2.85 G3: 0.5 Overall group F56,2=2.6; P =.08; LFR-TMS vs sham: P = 0.03; and HFLTMS vs sham: P = 0.09 Quality of Life Overall group F56,2=2.6; P =.08; LFR-TMS vs sham: P = 0.03; and HFLTMS vs sham: P = 0.09 Adverse Events Dizziness, % G1: 5% G2: 5% G3: 0 G4: 3.3% Other: 0- 2wks: 7 (11%) of 60 patients reported site discomfort or pain during rTMS and 6 (10%) reported a headache after rTMS. Although there was no difference in incidence of these adverse effects (P =.08), patients inHFL-TMS group seemed to report more discomfort during procedure itself. Only 1 patient ( HFL-TMS group) reported persistence ofheadache for longer than 1 hour. Two patients (1 in each group) reported transient dizziness for a short time after treatment. 2wks - 4 wks: One patient withdrew after 1 session of HFL-TMS treatment insingle-blind phase ofstudy owing to site pain. One bipolar patient, who had a successful response to LFR-TMS treatment, experienced a manic episode 10 days after completion of trial after ceasing treatment with valproate sodium Neuropsychological or executive functioning; - No deterioration in performance was found in any cognitive measures in group as a whole or in analyses of patients who received HFL-TMS only LFR-TMS only, or both active treatment conditions; - Including all patients who underwent at least 1 type of active treatment, there was a significant improvement in performance onverbal paired associates (t50=−7.3; P < 0.001), verbal fluency (t48=−3.8; P < 0.001), and digit span forwards (t48=−1.8; P = 0.003) subscales;Personal Semantic Memory Schedule (t50=−2.4; P = 0.02); andAutobiographical Memory Schedule (t50=−1.9; P = 0.05).; - A similar pattern of improvements was seen for each oftreatment subgroups (HFL-TMS only, LFR-TMS only, or both active treatments).; - Changes in performance oncognitive measures did not correlate with changes in MADRS and Beck Depression Inventory scores acrosssame times.; MMSE NR Other Attrition Overall, % None in initial 2 week treatment phase At end of treatment, % 0 At end of follow-up, % NR But at least 28.3% did not continue on thru2nd 2 weeks Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % G1: 0 (1 during follow-up) G2: 0 (0 during follow-up) G3: 0 (0 during follow-up) Progression of patients through 2nd phase is very unclear Adherence/ compliance NR

Evidence Table 33 KQ 4. Adherence: Tier 1 (ECT vs. pharma—MDD/Bipolar)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Folkerts et al., 1997^42^ Country, setting Germany, single center, inpatients Funding Not reported Research Objective To compare ECT in a controlled, randomized study withserotonin reuptake inhibitor paroxetine in treatment-resistant depression. Quality Rating Fair | Study design RCT Type of analysis per protocol N 39 Duration Total 6 weeks; Washout >= 3days; Phase I ECT - 2wks, Paroxetine - 4 wks; Phase II Paroxetine group - if clinical improvement reduction < 50% treatment switched to ECT, ECT group crossed over to Paroxetine or other antidepressants. Interventions G1: ECT G2: Paroxetine Medications Allowed After med wash -out patients were allowed a tranquillizer (diazepam up to 5 mg daily), a sedative (lormetazepam 0.5- 1.0 mg or triazolam 0.25 mg) or a sedative neuroleptic (pipamperon, up to 40 mg daily). Parameters ECT:; - % receiving bilateral: 0; - Intensity: 2.5-fold seizure threshold; - Number of sessions (range, mean, SD): 3/wk, range 6 to 9, mean 7.2 session; Paroxetine; - Started at 20 mg/day, within 7 days increased to 40 mg, allowed up to 50 mg, mean dose 44 mg/day for at least 4 weeks; Strategy Switch | TRD definition; - 2+ failed treatmentd (8+ weeks) including at least 1 tricyclic, at a dosage of at least 100 imiprimine equivalents; - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - Major depressive episode single and recurrent; - Bipolar disorders; - HAM-D21 >=22; Exclusion criteria; - Psychosis; - Pronounced suicidal tendency; - Severe physical illness; - History of substance abuse; - previous paroxetine or ECT treatment | Treatment Failure Level of tx resistance (Kuhs, 1995) G1: 1.9 (0.7 SD) G2: 2.0 (0.8 SD) Mean failed trials G1: 4.9 G2: 4.3 Polarity, % Unipolar G1: 90.5 G2: 83.3 Bipolar G1: 9.5 G2: 16.7 Age, mean yrs G1: 47.6 G2: 52.3 Sex, % females G1: 62 G2: 44 HAM-D 21 Baseline n G1: 21 G2: 18 Baseline score, mean (SD) G1: 31.1 (4.9) G2: 32.6 (5.4) | HAM-D 21 Endpoint score, mean (SD) Endof Phase I (ECT: 2-3 wks, Paroxetine: 4 wks) G1: 12.5 (3.9) G2: 23.0 (10.4) Endof Phase II (open trial, 6 weeks) G1: 12.8 (5.1) G2: 15.2 (7.9) Change, mean (SD) End of Phase I G1: -18.6 G2: -9.6 % Reduction in HAM-D, P = 0.001 End of Phase II G1: 18.3 G2: 17.4 Responders, n End of Phase I G1: 15 (71.4%) G2: 5 (27.8%) P = 0.006 | Quality of Life NR Adverse Events NR Attrition Overall, % 0 - all patients continued toscheduled end of treatment At end of treatment, % 0 At end of follow-up, % 0 Withdrawals due to efficacy, % 0 Withdrawals due to adverse events, % 0 Adherence/ compliance; - All pts continued their respective therapsies through scheduled end of treatment Phase I; - 11 of 21 ECT were able to discontinue after 6th ECT session and 10 pts. had 3 additional ECT treatments.; - Phase II - of ECT group, 9 received paroxetine and 12 received other antidepressants; - Of paroxetine groups, 7 crossed over to ECT; - 11 received antidepressants - 7 paroxetine and 4 received other antidepressants; 1 person was excluded from analysis due to failure to increase treatment dosage

Evidence Table 34 KQ 4. Adherence: Tier 2 (rTMS vs. sham—MDD only)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Stern et al., 2007^32^ Country, setting NR, outpatient setting Funding The Milton Fund, NARSAD,Stanley Vada NAMI Foundation, NIMH, Spanish Ministerio de Educacion y Cienca Research Objective To testhypothesis that rTMS exerts antidepressant effects either by enhancing left dorsolateral prefrontal cortex (DLPFC) excitability (using high-frequency rTMS) or by decreasing right DLPFC excitability (using low-frequency rTMS) have equivalent an Quality Rating Fair | Study design RCT Type of analysis Cannot tell, all reported patients included in the analysis N 45 Duration; - 10 days (2 wk) stimulation and 2 wk f/u for all 4 gps; - An additional 2 wk of unblinded f/u with gp 1 & 3 to assess for relapse.; Primary Outcome: HAM-D at 2 weeksnd and 2 weeks after treatment Interventions G1: 10 Hz rTMS to left DLPFC G2: 1 Hz rTMS to left DLPFC G3: 1 Hz toright DLPFC G4: Sham rTMS Medications allowed No psychotropic medications were allowed Parameters rTMS High Frequency:; - Frequency (Hz):10; - Motor threshold (%): 110; - Number of trains: 20; - Length of train (seconds): 8; - Inter-train interval: 52; - Pulses per session: 1600; - Total number of sessions: 10 days; Low Frequency LDLPFC:; - Frequency (Hz):1; - Motor threshold (%): 110; - Number of trains: 1; - Length of train (seconds): 1600; - Inter-train interval: 1; - Pulses per session: 1600; - Total number of sessions: 10 days; Low Frequency RDLPFC:; - Frequency (Hz): 1; - Motor threshold (%): 110; - Number of trains: 1; - Length of train (seconds): 1600; - Inter-train interval: 1; - Pulses per session: 1600; - Total number of sessions: 10 days; Sham rTMS:; - Orientation of coil perpendicular to scalp subdivided into 3 groups, replicating parameters for each group above; Strategy Switch | TRD definition; - All referred for ECT having failed an adequate course of antidepressant med; - Required to be in current episode; Tier 2 Inclusion criteria; - Patients w unipolar recurrent major depressive disorder (SCID & DSM-IV) HAM-D21 score ≥ 20; Exclusion criteria; - H/O any psychotic disorder (incl. schizophrenia or schizoaffective disorder); - Bipolar disorder; - Obsessive compulsive disorder; - Personality disorder; - SA(except nicotine) within past yr; - Current acute/chronic medical condition requiring txt with psychoactive medication; - H/O epilepsy or unprovoked seizures or other neurological disorder; - Abnormal neurological examination; - Family H/O medication-resistant epilepsy; - Prior brain surgery; - Metal in head; - Implanted medical device; - Pregnancy | Treatment Failure Mean failed trials NR Polarity, % Unipolar 100 % MDD Age, mean yrs G1: 53.2 G2: 52.3 G3: 52.8 G4: 53.3 Sex, % females G1: 60 G2: 60 G3: 70 G4: 60 Right handed, % 100 HAM-D 21 Baseline n G1: 10 G2: 10 G3: 10 G4: 15 Baseline score, mean (SD) G1: 27.8 (3.2) G2: 27.6 (3.9) G3: 27.9 (3.8) G4: 27.4 (2.9) | HAM-D 21 Endpoint score, mean (SD) At week 1 G1: 22.2 (5.6) G2: 27.6 (5.9) G3: 20.9 (4.1) G4: 25.6 (4.5) At week 2 G1: 15.1 (6) G2: 27.6 (5.9) G3: 15.8 (4.8) G4: 26.7 (3.6) Week 1 Follow-up G1: 12.8 (5.7) G2: 26.4 (2.3) G3: 15.3 (6.4) G4: 26.5 (2.3) Week 2 Follow-up G1: 13.4 (5.6) G2: 26.6 (3.0) G3: 14.9 (5.9) G4: 26.8 (2.3) Change, mean (SD) At week 2 G1: -12.7 G2: 0.0 G3: -12.1 G4: -0.7 % change, P = 0.001 2 week follow-up G1: 0 G2: 1.0 G3: 13.0 G4: 0.6 % change, P = 0.00001 Responders, n At week 1 G1: 0 G2: 0 G3: 0 G4: 0 At week 2 G1: 2 (50%) G2: 0 (0%) G3: 5 (50%) G4: 0 (0%) G1/G3 vs. G2/G4 (P < 0.0005) 1 week follow-up G1: 6 (60%) G2: 0 (0%) G3: 6 (60%) G4: 0 (0%) G1/G3 vs. G2/G4 (P < 0.0005) 2 week follow-up G1: 4 (40%) G2: 0 (0%) G3: 6 (6%) G4: 0 G1/G3 vs. G2/G4 (P < 0.0005) Remitters, n HAM-D ≤ 10 At week 1 G1: 0 (0%) G2: 0 (0%) G3: 0 (0%) G4: 0 (0%) At week 2 G1: 3 (30%) G2: 0 (0%) G3: 1 (10%) G4: 0 (0%) 1 week follow-up G1: 4 (40%) G2: 0 (0%) G3: 3 (30%) G4: 0 (0%) 2 week follow-up G1: 4 (40%) G2: 0 (0%) G3: 3 (30%) G4: 0 (0%) Responders followed for additional two weeks (endpoint 2wk follow-up) G1: vs. G3 P = NS (all times); G2 vs. G4 and G1: vs. G3 P = NS (all times) | Quality of Life NR Adverse Events 9/45 pts reported severe headaches (pts by group NR); no seizures Attrition Overall, %: 17.8 At end of treatment, % G1: 0 G2: 20 G3: 0 G4: 10 At end of follow-up, % G1: 0 G2: 50 G3: 0 G4: 20 Withdrawals due to efficacy: NR Withdrawals due to adverse events, % G1: 0 G2: 50 G3: 0 G4: 20 Though 8 pts withdrew due to AE, only 3 of those were listed as w/d during active period. Reported in text as dropped out following week 2. Adherence/ compliance NR
Author, Year O'Reardon, 2007^31^ Country, setting US, Canada, Australia; multicenter, outpatient/inpatient status not clearly reported Funding Neuronetics Research Objective To test whether transcranial magnetic stimulation (TMS) overleft dorsolateral perfrontal cortex is effective and safe inacute treatment of major depression Quality Rating Good | Study design RCT Type of analysis Modified ITT (m-itt) N 325 randomized Duration 6 weeks; Primary efficacy outcome (MADRS) collected at wk4. Sham patients could cross over aftr 4 weeks if not responding. Interventions G1: Active TMS G2: Sham TMS Medications Allowed All patients were free of ADs and other psychotropic medications directed at treating depression. Pts allowed only limited use of hypnotics, anxiolytics for txt emergent insomnia or anxiety Strategy Switch Parameters rTMS; - Frequency (Hz): 10; - Motor threshold (%): 120; - Number of trains: 75; - Length of train (seconds): 4; - Inter-train interval: 26; - Pulses per session: 3000; - Total number of sessions: 5/week for 4-6 wks; rTMS Sham:; - Coil has embedded magnetic shield, limiting magnetic energy reaching cortex to 10% or less than active coil | TRD definition; - Specifically required to have failed at least one in this or most recent episode OR four failed attempts in a lifetime; Tier 2 Setting(s) Not clearly reported Inclusion criteria; - Aged 18—70; - DSM-IV diagnosis of MDD; - Single episode or recurrent, with a current episode duration ≤3; - CGI-S score ≥ 4; - HAM-D17 ≥ 20 Symptom stability during a 1-week no-treatment lead-in period, with a HAM-D17 total score of at least 18 and a decrease in score of 25% or less from that observed atscreening assessment; Exclusion criteria; - A lifetime history of psychosis, bipolar disorder, or obsessive–compulsive disorder; - Posttraumatic stress disorder and eating disorders (if present in past year); - Lack of response to an adequate trial of electroconvulsive therapy (ECT); - Prior treatment with TMS or a vagus nerve stimulator implant; - Pregnancy; - Personal or close family history of seizure disorder; - Presence of neurologic disorder or medication therapy known to alter seizure threshold; - Presence of ferromagnetic material in or in close proximity to head | Baseline N G1: 165 G2: 160 Current episode failures, meanG1: 1.6 G2: 1.6 Mean failed trials NR Previous treatment, not specified, % NR Polarity, % Unipolar 100 Age, mean yrs G1: 47.9 G2: 48.7 Sex, % females G1: 55.5% G2: 50.7% Race, % white G1: 94.2% G2: 89.7% HAM-D 17 Baseline score, mean (SD) G1: 22.6 (3.3) G2: 22.9 (3.5) MADRS Baseline n G1: 155 G2: 146 Baseline score, mean (SD) G1: 32.8 (6.0) G2: 33.9 (5.7) IDS Baseline n G1: 155 G2: 146 Baseline score, mean (SD) G1: 42.0 (9.4) G2: 43.4 (9.9) CGI-S Baseline n G1: 155 G2: 146 Baseline score, mean (SD) G1: 4.7 (.6) G2: 4.7 (.7) | HAM-D 17 Analyzed n G1: 155 G2: 146 Endpoint score, mean (SD) At week 4 G1: 17.4 (6.5) G2: 19.4 (6.5 At week 6 G1: 17.1 (7.7) G2: 19.6 (7.0) Change, mean (SD) At week 2 G1: -5.2 G2: -3.5 At week 6 G1: -5.5 G2: -3.3 P = 0.005 Responders, n (%) At week 2 G1: 18 (11.6) G2: 13 (8.9) P > 0.10 At week 4 G1: 32 (20.6) G2: 17 (11.5) P < 0.05 At week 6 G1: 38 (24.5) G2: 20 (13.7) P < 0.05 Remission rate n (%) HAM-D17 < 8 At week 2 G1: 5 (3.2) G2: 3 (2.1) P > 0.10 At week 4 G1: 110 (7.1) G2: 9 (6.2) P > 0.10 At week 6 G1: 24 (15.5) G2: 13 (8.9) P = 0.065 MADRS Endpoint score, mean (SD) At 4 weeks G1: 27 (11.1) G2: 29.8 (10.1) At 6 weeks G1: 26.8 (12.8) G2: 30 (10.8) Change, mean (SD) At 4 weeks G1: 5.8 G2: 4.1 At 6 weeks G1: 6 G2: 3.9 Response rate, % At week 2 G1: 8.4 G2: 6.2 P > 0.10 At week 4 G1: 18.1 G2: 11.0 P <0.05 At week 6 G1: 23.9 G2: 12.3 P <0.01 Remission rate, % Remission defined as total score <10 At week 2 G1: 3.9 G2: 2.1 P > 0.10 At week 4 G1: 7.1 G2: 6.2 P > 0.10 At week 6 G1: 14.2 G2: 5.5 P < 0.05 | Quality of Life NR Adverse Events Serious adverse events G1: 6 G2: 5 Suicidality, % G1: 0.6 G 2: 1.9; - Exacerbation of depression: active TMS = 0.6%, sham TMS = 1.9%; - Eye pain: active TMS = 6.1% sham TMS = 1.9%;; - GI disorders toothache: active TMS = 7.3%, sham TMS = 0.6%;; - Application site discomfort: TMS = 10.9%, sham = 1.3%; - Application site pain, %: TMS = 35.8, sham = 3.8; - Facial pain: active TMS = 6.7%, sham TMS = 3.2; - Muscle twitching: TMS = 20.6%, sham = 3.2%; - Pain of skin: TMS = 8.5%, TMS = 0.6%; MMSE NR Attrition Overall, % 15 At end of treatment, % G1: wk2 6%/ wk 4 5% G2: wk 2 9%/ wk 4 6% At end of follow-up, % G1: NR G2: NR Withdrawals due to efficacy, % G1: 0.6% G2: 1% Withdrawals due to adverse events, % G1: 5% G2: 4% Other; - 325 subjects were randomized; - 24 were “nonevaluable”; - 301 continued to receive at least 1 treatment, these 301 were included in final analysis; - 277 completed study through week 4.; Adherence/ compliance NR

Evidence Table 35 KQ 4. Adherence: Tier 2 (rTMS vs. sham—MDD/Bipolar)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Berman et al., 2000^28^ Country, setting US, urban community health center, inpatient and outpatients Funding Veterans Administration, NIMH, State of CT Research Objective To assessefficacy of rTMS in unmedicated TRD patients Quality Rating Fair | Study design RCT Type of analysis ITT N 20 Duration 2 weeks (10 weekdays of txt) Primary outcome = HAM-D at 2wks Interventions G1: rTMS G2: Sham TMS Medications Allowed All patients free of antidepressants, neuroleptics, and benzodiazepines Inpatients pts allowed chloral hydrate for sleep Strategy Switch Parameters rTMS –; - Frequency (Hz): 20; - Motor threshold (%): 80; - Number of trains: 20; - Length of train (seconds): 2; - Inter-train interval:58; - Pulses per session:800; - Total number of sessions: 10 in 10 days; Sham; - Paddle angled approximately 30 – 45 degrees off of scalp with bottom coil margin elevated approximately one-half cm from scalp and lucite paddle casing firmly applied against the scalp | TRD definition; - 1+ failed trials (4+ weeks duration with at least 200 mg mg/d of imiprimine, 20mg/day fluoxetine, 60mg/d phenelzine, 225mg/d venlafaxine, 30mg/d mirtazapine); - Not required to be in current episode; Tier 2 Inclusion criteria; - Current Major depressive episode (via Ham-D); Exclusion criteria; - Hx of sig. neurological illness; - EEG abnormalities suggestive of an epileptic predisposition; - Substance or alcohol use abuse diagnosis,; - Sig. unstable medical illness,; - Females - pregnancy or inadequate birth control | Treatment Failure Current episode failures, mean G1: 5 G2: 3.5 (+ a median of 1 aumgmentation in eachgroup) Polarity, % Unipolar G1: 100 G2: 90 Bipolar II G1: 0 G2: 10 Age, mean yrs G1: 45.2 G2: 39.4 Sex, % females G1: 20 G2: 40 Race, % white G1: 100 (n=1 hispanic) G2: 100 (n=1 hispanic) HAM-D 25 Baseline n G1: 10 G2: 10 Baseline score, mean (SD) G1: 37.1 G2: 37.3 | HAM-D 25 G1: rTMS G2: Sham TMS Endpoint score, mean (SD) At week 2 G1: 24.6 G2: 36.4 *Adjusted Change (based on best fit slopes), mean (SEM) G1: -14.0 (3.7) G2: -0.2 (4.1) P < 0.05 Responders, n 50% decrease from baseline and score <= 15 G1: 1 (10) G2: 0 P = 0.09 Three partial responders symptom severity returned to baseline within 1-2 weeks BDI Change, mean (SD) G1: 11.4 (5) G2: 4.7 (6) P = 0.27 | Quality of Life NR Adverse Events Headache, n G1: 60 G2: 50 Difficulty starting urination great in active group P = 0.03 Remaining 21 potential side effects assessed by the SECL were not significantly different between groups after correction for multiple comparisons (data NR); - Poor memory, nausea or vomiting, constipation, drowsiness, blurred vision, increased appetite, dry mouth, decreased appétit, tremors and shakiness, nightmares, difficulty sitting still, trouble concentrating, irregular or pounding heartbeat, diarrhea, frequent need to urinate, rash, ringing in the ears, sweating, faintness or lightheadedness, poor coordination, and muscle stiffness; MMSE NR Attrition Overall, % 15 At end of treatment, % G1: 0.0 G2: 30.0 At end of follow-up, % G1: NA G2: NA Withdrawals due to efficacy, % G1: 0 G2: 30 Withdrawals due to adverse events, % G1: 0 G2: 0 Adherence/ compliance NR
Author, Year George, 2010^18^ George Country, setting United States, outpatient Funding NIMH as the Optimization of TMS for the Treatment of Depression Study Research Objective To test whether daily left prefrontal rTMS safely and effectively treats major depressive disorder Quality Rating Good | Study design RCT Type of analysis mITT (all randomized patient who started at least 1 treatment session) Completer (randomized patients who were treated according ot protocol and had fewer than 4 rescheduled, missed, or partially completed rTMS sessions dueing weeks 2 to 6) Fully Adherent (fewer than 2 rescheduled, missed, or partially complete sessions; must not have been taking prohibited psychiatric medications or illicit drugs; and had no other protocol violations) N Randomized: 199 ITT: 190 Completers: 154 Adherent: 120 Duration Fixed Duration Active Treatment: 3 wks Variable Duration Active Treatment: 3 wks No-treatment lead-in: 2 wks HAM-D assessment performed twice weekly Acute trial terminated when patients met the stable remission criteria. Interventions rTMS Sham G1: rTMS G2: Sham G1: rTMS G2: Sham G1:rTMS G2: Sham Medications Allowed None (2 week washout) Strategy Switch strategy Parameters G1: Location: Left prefrontal cortex Frequency: 10 Hz Intensity 120% MT Pulses: 10 pulses per second for 4 seconds; 3000 persession Intertrain interval: 26 seconds Length of Session: 37.5 minutes (75 trains) Fixed Active Treatment - Number of sessions: daily weekday sessions (15 sessions) Blinded treatment for improvers - Number of sessions: daily weekday sessions for up to another three weeks (total possible sessions = 30) G2: Similar coil as active treatment witha metal insert blocking the magnetic field and scalp electrodes that delivered matched somatosensory sensations. | TRD definition; - Moderate level of treatment resistance as defined by the ATHF; insufficient clinical benefit to 1-4 adequate medication trials or intolerant to ≥ 3 trials; Author personal communication states, “All patients had either one failed antidepressant failure, or multiple intolerance to antidepressant medications.”; - Not required in the current episode; Tier 2 Inclusion criteria; - Antidepressant medication-free outpatients; 18-70 yo; DSM-IV MDD, single or recurrent; HAM-D24 ≥ 20; Stable during 2wk medication-free lead-in; moderate level of treatment resistance as defined by the Antidepressant Treatment History Form (ATHF); insufficient clinical benefit to 1-4 adequate medication trials or intolderant to ≥ 3 trials.; Exclusion criteria; - Other current Axis I disorders; past failure to respond to an adequate trial of ECT; prior treatment with TMS or VNS; personal or close family history or seizure disorder; Neurologic disorder; Ferromagnetic material in body or close to head; pregnancy; taking meds known to lower seizure threshold. | Subgroups No Subgroups Baseline n mITT G1: 92 G2: 98 Treatment Failure Failed 1 or more, % G1: NR G2: NR Failed 2 or more, % G1: NR G2: NR Current episode failures, mean Mean, median (SD) G1: 1.62, 1 (1.37) G2: 1.41, 1 (0.97) Mean failed trials Mean, median (SD) G1: 3.34, 2 (2.68) G2: 3.28, 3 (2.11) Polarity, % Unipolar G1: 100 G2: 100 Bipolar I G1: 0 G2: 0 Bipolar II G1: 0 G2: 0 Patient Characteristics Age, mean yrs G1: 47.7 G2: 46.5 Sex, % females G1: 63 G2: 51 Race, % white G1: NR G2: NR Not Specified, % G1: NR G2: NR Right handed, % G1: NR G2: NR Groups similar at baseline Yes HAM-D 17 Baseline score, mean (SD) G1: 26.3 (5.0) G2: 26.5 (4.8) BDI Baseline score, mean (SD) | HAM-D (Insert #) Yes HAMD24 G1:rTMS G2: Sham N Analyzed mITT G1: 92 G2: 98 Observed: G1: 92 G2: 98 Observed Endpoint: G1: 83 G2: 91 Completers: G1: 72 G2: 82 Fully Adherent: G1: 57 G2: 63 Endpoint score, mean (SD) Observed G1: 21.61 (9.26) G2: 23.38 (7.43) G1: vs. G2, 95% CI Effect Estimate, Cohen d, p-value: -4.23 to 0.10, -0.42, p = 0.06 Change, mean (SD) Observed at 3 weeks G1: -4.65 (NR) G2: -3.13 (NR) Responders, n mITT: G1: 14 G2: 5 p = 0.009 OR of responding to rTMS vs. Sham 4.6 (95%CI, 1.47 to 14.42) Completer: G1: 10 G2: 4 p = 0.02 Fully Adherent: Overall = 7 p = 0.14 Remitters, n No. (95%CI) mITT: G1: 13 (8.5 to 22.7) G2: 5 (2.3 to 11.4) OR (95%CI): 4.18 (1.32 to 13.24) Completers: G1: 10 (7.8 to 23.7) G2: 4 (2.0 to 11.9) OR (95%CI): 4.92 (1.29 to 18.76) Fully Adherent: G1: 6 (5.0 to 21.2) G2: 2 (1.0 to 10.8) OR (95%CI): NS Remitters by Treatment Phase Phase I Fixed(Wks 1-3) G1: 6 G2: 2 Phase I Variable (Wks 4-6) Week 4 Day 2 G1: 2 G2: 0 Week 4 Day 5 G1: 3 G2: 0 Week 5 Day 2 G1: 2 G2: 3 Other Response: ≥ 50% decrease in HAM-D score from baseline) Remission: HAM-D score of 3 or less or 2 consecutive Ham-D scores less than 10 MADRS Yes G1: rTMS G2: Sham Baseline n Observed Baseline G1: 92 G2: 98 Observed End of Phase I G1: 83 G2: 91 Baseline score, mean (SD) G1: 29.5 (6.9) G2: 29.8 (6.4) Endpoint score, mean (SD) Observed at 3 weeks G1: 24.59 (11.44) G2: 27.75 (9.06) G1: vs. G2, 95% CI Effect Estimate, Cohen d, p-value: -6.10 to -0.76, -0.51, p = 0.01 Change, mean (SD) Observed at 3 weeks G1: -4.89 (NR) G2: -2.06 (NR) Responders, n NR Remitters, n NR Other NA IDS Yes G1:rTMS G2: Sham[Q60] Baseline n Observed Baseline: G1: 86 G2: 94 Observed at end of Phase I: G1: 78 G2: 88 Baseline score, mean (SD) G1: 41.0 (9.3) G2: 40.1 (9.8) Endpoint score, mean (SD) Observed at 3 weeks G1: 32.56 (15.40) G2: 36.70 (13.91) G1: vs. G2, 95% CI, Cohen d, p-value: -10.04 to -2.62, -0.66, p = 0.001 Change, mean (SD) Observed at 3 weeks G1: -8.42(NR) G2: -3.37 (NR) Responders, n NR Remitters, n NR Other NA CGI-S Yes G1: rTMS G2: Sham Baseline n Observed at baseline: G1: 90 G2: 98 Observed at end of Phase I: G1: 82 G2: 90 Baseline score, mean (SD) G1: 4.62 (0.70) G2: 4.63 (0.69) Endpoint score, mean (SD) Observed at 3 weeks G1: 3.96 (1.14) G2: 4.30 (0.87) G1: vs. G2, 95% CI Effect Estimate, Cohen d, p-value: -0.68 to -0.09, -0.55, p = 0.01 Change, mean (SD) Observed at 3 weeks G1: -0.66 (NR) G2: -0.33(NR) Other NA | Quality of Life No Adverse Events Overall, % NR Amnesia, % NR Cardiovascular adverse events, % NR Cognitive impairment, % NR Dizziness, % NR Headache, % G1: 32 G2: 23 Insomnia, % G1: 7.6 G2: 10 Post op complications, % NR Somnolence, % G1: 5 G2: 4 Suicidality, % Suicidality: NR Suicides: G1: 0 G2: 0 Additional Comments Those not reported previously below: Discomfort at the stimulation site (%): G1: 18 G2: 10 Worsening depression or anxiety(%): G1: 7 G2: 8 Gastrointestinal(%): G1: 7 G2: 3 Muscle Aches(%): G1: 4 G2: 4 Vertigo(%): G1: 2 G2: 2 Skin Pain(%): G1: 1 G2: 1 Facial Muscle Twitching(%): G1: 0 G2: 1 Other(%): G1: 20 G2: 15 No seizures reported Serious Adverse Events: Syncope (n): G1: 1 patient G2: 0 Paranoid Ideation: G1: 0 G2: 1 patient Neuropsychological or executive functioning No Measures, Results NA Predefined No MMSE No Baseline n Baseline score, mean (SD) Endpoint score, mean (SD) Change, mean (SD) Other Other Yes Those not reported previously below: Discomfort at the stimulation site (%): G1: 18 G2: 10 Worsening depression or anxiety(%): G1: 7 G2: 8 Gastrointestinal(%): G1: 7 G2: 3 Muscle Aches(%): G1: 4 G2: 4 Vertigo(%): G1: 2 G2: 2 Skin Pain(%): G1: 1 G2: 1 Facial Muscle Twitching(%): G1: 0 G2: 1 Other(%): G1: 20 G2: 15 No seizures reported Serious Adverse Events: Syncope (n): G1: 1 patient G2: 0 Paranoid Ideation: G1: 0 G2: 1 patient Adequate information Yes Attrition Overall, % All attrition calculations based on mITT 10.5% At end of treatment, % G1: 12 G2: 9 At end of followup, % G1: NA G2: NA Withdrawals due to efficacy, % G1: NR G2: NR Withdrawals due to adverse events, % G1: 5.4 G2: 0 Other Adherence/ compliance Adherence Fully Adherent n= 120 G1: n = 57 G2: n = 63

Evidence Table 36 KQ 4. Adherence: Tier 2 (CBT vs. usual care—MDD only)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Moore et al., 1997^43^ Country, setting Scotland, University clinic, outpatients Funding Scottish Office, Home and Health Department Research Objective To compare CBT to additional meds in treatment of depression non-responsive to medication duringacute phase of study (results of Phase 1 reported elsewhere). Quality Rating Fair | Study design RCT Type of analysis Completers confirmed with ITT N 13 Duration 12 months Interventions G1: Medication G2: Cognitive Therapy Medication Allowed G1: Continued AD assigned in acute phase OR initiated another AD txt G2: Discontinued AD Strategy Mixed-between group differences Parameters; - Medication dose within recognized therapeutic theshold; - Psychotherapy; - Type of therapy: Cognitive Therapy; - Method: NR; - Number of sessions/week: min. 3/wk for 4wks and then 2/wk for 4wks and 1/wk for 4wks; - Total number of sessions: NR | TRD definition; - Failure to respond to AD medication during 16 wk acute txt phase; - Failure required to be in current episode; Tier 2 Inclusion criteria; - HAM-D > 14; Exclusion criteria NA | Baseline N G1: 7 G2: 6 Treatment Failure Current episode failures, mean G1: NR Mean failed trials G1: NR Polarity, % Unipolar Overall: 100 Age, mean yrs Overall: 38 Sex, % females Overall: 62 HAM-D 17 Baseline score, mean (SD) G1: 18.6 (3.3) G2: 18.3 (3.9) BDI Baseline score, mean (SD) G1: 30.6 (5.1) G2: 37.8 (5.1) | Analyzed, n G1: 4 G2: 5 HAM-D 17 Endpoint score, mean (SD) 4 mos G1: 11.0 (2.3) G2: 19.8 (5.6) 8 mos G1: 6.6 (7.3) G2: 17.5 (1.9) 12 mos G1: 5.0 (5.7) G2: 14.3 (4.0) Completers, group by time, P < 0.01 ITT (LOCF), group by time, P < 0.01 Change, mean (SD) 4 month G1: -7.6 G2: +1.5 Partial responders, n Defined as HAM-D ≤ 14 G1: 5 G2: 2 P = 0.17 Full responders, n Defined as HAM-D ≤ 6 G1: 3 G2: 0 P = NR BDI Endpoint score, mean (SD) 4 mos. G1: 22.2 (5.9) G2: 41.5 (5.8) 8 mos. G1: 9.2 (8.3) G2: 34.3 (12.0) 12 mos. G1: 10.8 (12.2) G2: 35.8 (12.6) Group by time, P = 0.05 ITT (LOCF), group by time, P < 0.05 Change, mean (SD) At 4 months G1: -8.4 G2: +3.7 Partial responders, n Defined as BDI ≤ 16 G1: 4 G2: 0 P < 0.05 Full responders, n Defined as BDI ≤ 9 G1: 3 G2: 0 P = NR | Quality of Life NR Adverse Events NR Attrition Overall, % 31% At end of treatment, % G1: 43 G2: 17 At end of follow-up, % G1: 43 G2: 17 Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR Adherence/ compliance NR

Evidence Table 37 KQ 4. Adherence: Tier 2 (CBT vs. usual care—MDD/Bipolar)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Harley, 2008^36^ Country, setting United States, university clinics, outpatient psychiatric Funding Kaplan Fellowship Award Grant through Harvard Medical School Research Objective To assess feasibility and potential utility of a Dialectical Behavior Therapy(DBT)-based skills training group for TRD Quality Rating Fair | Study design RCT Type of analysis Completers N 24 Duration Primary outcome after 16 weeks of active txt Follow-up: 6 months Interventions G1: Dialectical Behavior Therapy(DBT)-based skills training G2: Wait-list Control Medications Allowed Patients continued antidepressant therapy Strategy Augmentation Parameters; - Type of therapy: Dialectical Behavior Therapy(DBT)-based skills training; - Method: Group; - Number of sessions/week:1; - Total number of sessions:16; G2: Wait list | TRD definition; - 1+ failed medications (6+ weeks at “standard effective dose”); - Not required or not specified to be in current episode; Tier 2 Inclusion criteria; - 18-65 years with a principal diagnosis of MDD; - Established treatment relationship with a psychiatrist at MGH or in larger community.; - Stabalized on an adequate dose of antidepressant medication before entering study.; Exclusion criteria; - Borderline personaliy disorder, bipolar disorder, psychotic spectrum disorders, active substance abuse or dependence, mental retardation, or pervasive developmental disorder.; - Active suicidality requiring more intensive levels of care; - Severe or unstable medical conditions; - Previous or current CBT experience. | Baseline N G1: 13 G2: 11 Treatment Failure Mean failed trials NR Polarity, % MDD Overall: 100 Age, mean yrs Overall: 41.8 Sex, % females Overall: 75 Race, % white Overall: 83 HAM-D 17 Baseline score, mean (SD) G1: 16.15 (4.47) G2: 18.64 (4.72) P = NS BDI Baseline score, mean (SD) G1: 27.31 (8.83) G2: 27.44 (11.66) P = NS | HAM-D 17 Analyzed n G1: 10 G2: 9 Endpoint score, mean (SD) Completers analysis, 16 weeks G1: 11.30 (5.3) G2: 17.11 (6.23) Change, mean (SD) Completers, 16 weeks G1: -5.6 G2: -1.78 P < 0.05 Remitters, n Completers per protocol analysis, 16 weeks G1: 3 (23%*) G2: 0 (0%*) P = NR BDI Endpoint score, mean (SD) At Week 16, completers per protocol G1: 15.10 (12.13) G2: 25.89 (16.30) Change, mean (SD) G1: -12.80 G2: -1.55 P < 0.01 | Quality of Life Lifework-The Range of Impaired Functioning Tool (LIFE-RIFT) Baseline n G1: 10 G2: 9 Baseline score, mean (SD) G1: 4.00 (0.94) G2: 3.44 (1.24) Endpoint score, mean (SD) G1: 2.70 (1.34) G2: 3.11 (1.69) Change, mean (SD) G1: -1.3 G2: -0.33 P = NS Social Adjustment Scale-Self-Report (SAS-SR) work subscale Baseline n G1: 10 G2: 9 Baseline score, mean (SD) G1: 82.50 (21.21) G2: 69.22 (17.95) Endpoint score, mean (SD) G1: 65.70 (19.27) G2: 69.56 (17.66) Change, mean (SD) G1: -16.80 G2: 0.34 P < 0.05 Adverse Events NR MMSE NR Attrition Overall, %: 21 At end of treatment, % G1:23 G2:18 At end of follow-up, % G1:20 G2: NR Withdrawals due to efficacy, % G1: 8 G2: 0 Withdrawals due to adverse events, % 0 Other 5 participants (3 groups, 2 wait-lists) did not complete study. One group participant dropped out because of difficulty finding childcare another discontinued treatment due to a work schedule conflict, and third decided group was not a good fit. One wait-list participant moved and could not continue instudy and a medical problem prevented second from continuing. Adherence/ compliance Compliance Participants completed a weekly check-in form asking about medication compliance over preceding month.19 participants who completed study reported that they had been largely medication compliant—11 reported that they had taken their medication as directed every day and 8 reported that they had forgotten a medication dose between 1 to 4 times in previous month.
Author, Year Paykel, 1999^38^ Scott, 2000^59^ Note: #2223 and #2219 are companion studies, data from #2223 were abstracted in to form for #2219. Country, setting UK, outpatient Funding Medical Research Council, London, England and a grant fromOxford and Anglia Region Research Objective To compare cognitive therapy combined with clinical management to clinical management alone for patients with residual depressive symptoms who continued to receive maintainance treatment with antidepressants. Quality Rating Good | Study design RCT Type of analysis ITT N 158 Duration Treatment period = 20 weeks; 48 wks - follow-up: Subjects were assessed every 4 to 20 wks and every 8 wks thereafter at baseline, 8 wks, 20 wks, and 68 wks. Interventions G1: Clinical management Only G2: CT plus Clinical Management Medications allowed Continued on current medications with dose adjustments allowed Strategy Augmention Parameters Psychotherapy:; - Type of therapy: Cognitive Therapy; - Method: Individual; - Number of sessions/week: 1.25/wk; - Total number of sessions: 16 | TRD definition; - residual symptoms reaching at least 8 on the 17-item Hamilton Depression Rating Scale (HDRS)18 and 9 on the Beck Depression Inventory (BDI) and taking a tricyclic antidepressant, serotonin reuptake inhibitor, atypical antidepressant, or monoamine oxidase inhibitor for at least the previous 8 weeks, with 4 or more weeks at a daily dose at least equivalent to 125 mg of amitriptyline,; - Residual symptoms had lasted 2 to 18 months.; - Failure required to be in the current episode; Tier 2 Inclusion criteria; - Unipolar depression,; - aged 21 to 65 years,; - satisfying DSM-III-R17 criteria for major depression withinlast 18 months but not inlast 2 months, and; - Had to be taking a tricyclic antidepressant, serotonin reuptake inhibitor, atypical antidepressant, or monoamine oxidase inhibitor for at leastprevious 8 weeks, with 4 or more weeks at a daily dose at least equivalent to 125 mg of amitriptyline, and higher levels unless there were definite current adverse effects or patient refusal to increase dose.; Exclusion criteria; - A history of bipolar disorder, cyclothymia, schizoaffective disorder, definite; - Intervention or alcohol dependence, persistent antisocial behavior or repeated self-harm,; - DSM-III-R dysthymia with onset before age 20 years,; - borderline personality, learning disability (estimated IQ,70),; - organic brain damage,; - any other primary Axis I disorder attime ofindex illness.; - Also excluded were patients currently receiving formal psychotherapy or those who had previously received CT for more than 5 sessions. | Treatment Failure Mean failed trials G1: NR G2: NR Polarity, % Unipolar 100% 100% Age, mean yrs G1: 43.2 (11.2) G2: 43.5 (9.8) Sex, % females G1: 53% G2: 46% HAM-D 17 Baseline n G1: 78 G2: 80 Baseline score, mean (SD) G1: 12.2 (2.9) G2: 12.1 (2.7) BDI Baseline score, mean (SD) G1: 22.3 (8.0) G2: 21.9 (7.7) | HAM-D 17 G1: Clinical Management only G2: CT plus Clinical Management Endpoint score, mean (SD) At week 20 G1: 9.40 (5.2) G2 (5.2) Follow-up at 44 weeks G1: 8.7 (5.3) G2: 7.6 (4.7) Follow-up at 68 weeks G1: 7.2 (4.7) G2: 7.2 (5.3) Change, mean (SD) At week 20 G1: -2.8 G2: -3.4 P = NS Follow-up at 44 weeks G1: - 3.0 G2: -4.5 Follow-up at 68 weeks G1: -5.0 G2: -4.9 Responders, n NR Remitters, n (%) HAM-D<8 At week 20 G1: 10 (13) G2: 19 (24) Hazard Ratio for remission from intention to treat analysis: 2.42 (95% CI, (1.08, 5.45)) BDI Endpoint score, mean (SD) At 20 weeks G1: 16.1 (10.0), G2: 13.8 (9.6), Follow-up at 44 weeks G1: 17.3 (11.6) G2: 12.3 (9.3) Follow-up at 68 weeks G1: 14.3 (10.9) G2: 13.5 (11.7) Change, mean (SD) At week 20 G1: -6.24 G2: -8.44 Responders, n NR Remitters, n BDI <9 At week 20 G1: 10 (13%) G2: 19 (24.4%) Relapse n(%): At week 20: G1: 18 (23) G2: 10 (13) At week 44 G1: 40 (51) G2: 24 (30) At week 68 G1: 47 (60) G2: 29 (36) Hazard ratio for relapse = 0.54 (0.32-0.93) in favor of CT Actuarial Cumulative relapse rates at all time points for group 1: Awk20 = 18%, FUwk44 = 40%, FUwk68 = 47%; Actuarial Cumulative relapse rates at all time points for group 2: Awk20 = 10%, FUwk44 = 24%, FUwk68 = 29%;adjusted hazard ratio for relapse = 0.51, 95% CI, (0.32, 0.93). Over 17 months,relapse rate was reduced from 47% among those who continued to be treated with antidepressants without CT to 29% among those who also received CT. #2219: Relapse was defined as: (1) meetingDSM-III criteria for major depressive disorder for a minimum of 1 month, and meeting severity criteria for major depression and score 17 or more onHAM-D 17 at 2 consecutive face-to-face assessments at least 1 week apart; (2) persistent residual symptoms duringfollow-up phase between 2 successive ratings 2 months apart, reaching a score onHAM-D 17 of at least 13 on both occassions and a level of distress or dysfunction for whichthe withholding of additional active treatment was no longer justified | Quality of Life NR Adverse Events NR Attrition Overall, % 20% did not adhere to protocol through to study end or relapse point At end of treatment, % G1: 4 G2: 14 At end of follow-up, % G1: 12 G2: 10 Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % NR Adherence/ compliance Adherence, n(%) G1: 61 (76%) G2: 66 subjects (85) [Control]

Evidence Table 38 KQ 4. Adherence: Tier 3 (ECT vs. rTMS—MDD/Bipolar)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Hansen, 2010^6^ Hansen Country, setting Denmark University Hospital Inpatient Psychiatric Funding Danish Council for Medical Research; Einar Geert-Jorgensen and Wife Ellen Geert-Jorgensen Research Foundation; Boutcher Worzner and wife Inger Worzner grant; the Aarhus University Foundation for Researhc in Mental Disease; the Foundation of Psychiatric Research Research Objective To compare the antidepressant efficacy and adverse effects of right prefrontal low-frequency rTMS with that of ECT. Quality Rating Fair - KQ1 KQ4? | Study design RCT Type of analysis ITT PP N 60 Duration Active treatment: 3 wks HAMD and UKU assessed at baseline and weekly intervals w/in 24 hrs of treatment Follow-up treatment: 7 wks (total duration) HAMD and UKU assessed at wk 5 and wk 7 Interventions ECT rTMS G1: rTMS G2: ECT Medications Allowed Continued current antidepressant medication; discontinued antiepileptics prescribed as mood stabilizers, benzodiazepines tapered off, low dose zopiclone or zopidem if needed for sleep Strategy Augment or add-on strategy Parameters G1: Location: Right DLPFC Frequency: 1 Hz Intensity: 110% MT Trains: 2 60s trains Intertrain interval: 180 s Number of session: 15 total (1 per week day for 3 weeks) G2: Location: Unilaterally over the right hemisphere Intensity: Recorded seizure duration ≥ 25 seconds; If between 15-25 seconds next treatment carried out with 50% higher stimulus intensity; If < 15 seconds then followed by restimulation. Number of session: 9 total (3 sessions weekly) | TRD definition; - Patients referred for ECT; Tier 3 Inclusion criteria; - 18-80 yo; HAMD-17 total score of ≥ 20 and/or subscale score of ≥ 9; right-handed; ICD-10 diagnosis of moderate to severe depression; DSM-IV diagnosis of MDD; unipolar or bipolar; Exclusion criteria; - Organic brain damage; personal/family history of epileptic seizures, metallic objects in the chest or brain as a result of surgery; cardia pacemakers; somatic diseases associated w/ brain dysfunction; pregnancy; use of coercive measures; suicidal risk of severe degree; severe agitation; delirium; alcohol or drug dependence. | Subgroups No Subgroups Baseline n G1: 30 G2: 30 Treatment Failure Failed 1 or more, % G1: NR G2: NR Failed 2 or more, % G1: NR G2: NR Current episode failures, mean G1: NR G2: NR Mean failed trials G1: NR G2: NR Polarity, % Unipolar G1: 86.7 G2: 86.7 Bipolar I G1: 13.3 G2: 13.3 Bipolar II G1: NR G2: NR Patient Characteristics Age, mean yrs Median (range) G1: 46 (14-38) G2: 52 (29-79) p = 0.16 Sex, % females G1: 76.7 G2: 63.3 Race, % white G1: NR G2: NR Not Specified, % G1: NR G2: NR Right handed, % G1: 100 G2: 100 Groups similar at baseline Yes HAM-D 17 Baseline score, mean (SD) Median (Range): G1: 24 (14-38) G2: 24 (16-34) G1: vs. G2: p = 0.68 | HAM-D (Insert #) Yes HAM-D17 G1: rTMS G2: ECT Endpoint score, mean (SD) Week 3 G1: NR Baseline - wk3 reduction, p <0.001 G2: NR Baseline - wk3 reduction, p <0.001 Week 3-7 G1: NR wk3 - wk7 reduction, p <0.001 G2: NR wk3 - wk7 reduction, p = 0.78 Week 7 G1: NR Baseline - wk 7 reduction, p < 0.001 G2: NR Baseline - wk 7 reduction, p < 0.001 Change, mean (SD) G1: NR G2: NR Responders, n Response Rate Difference Week 3, Rate (95% CI): G1: 0.20 (0.08-0.39) G2: 0.57 (0.37-0.75) G1: vs. G2 rate difference: 0.37 (0.14-0.59), p = 0.003 Week 7, Rate (95%CI): G1: 0.43 (0.25-0.63) G2: 0.60 (0.41-0.77) G1: vs. G2 rate differenc: 0.17 (-0.08, 0.42), p = 0.200 Remitters, n Remission Rate Difference Week 3 Rate (95% CI): G1: 0.27 (0.12 - 0.46) G2: 0.53 (0.34 - 0.72) G1: vs. G2 rate difference: 0.26 (0.03 - 0.51), p = 0.035 Week 7 Rate (95% CI): G1: 0.40 (0.23 - 0.59) G2: 0.57 (0.37 - 0.75) G1: vs. G2 rate difference: 0.17 (-0.08, 0.42), p = 0.200 Other Remission: HAMD-17 ≤ 12 Response: ≥ 50% reduction in HAMD-17 | Quality of Life No Adverse Events Overall, % NR Amnesia, % NR Cardiovascular adverse events, % NR Cognitive impairment, % G1: 0 G2: 0 Dizziness, % NR Headache, % NR Insomnia, % NR Post op complications, % NR Somnolence, % Signficantly > decline in fatigue score in the ECT group (score NR) Suicidality, % NR Additional Comments NR “Both treatment forms were generally well tolerated. No serious adverse effects were reported. For 5 patients, rTMS was associated with severe local discomfort or pain, and 4 of them dropped out for that reason. The rest of the rTMS group experienced no or only slight inconvenience. Both groups revealed declining scores during the treatment period. The statistical analyses controlled for several essential variables( data not shown)…None of the 2 methods were associated with cognitive adverse effects or serious adverse effects on the UKU rating scale. Neuropsychological or executive functioning Yes Measures, Results Logical Memory – Immediate recall Baseline, Mean (SD): G1: 10.8 (4.4) G2: 10.0 (5.1) After Treatment G1: 8.8 (3.8) G2: 9.6 (5.1) Logical Memory – Delayed recall Baseline, Mean (SD): G1: 7.6 (5.4) G2: 7.46 (5.5) After Treatment G1: 7.2 (3.7) G2: 6.8 (5.8) Verbal Learning – Total Baseline, Mean (SD) G1: 8.2 (1.7) G2: 8.4 (2.1) After Treatment G1: 8.1 (2.0) G2: 7.9 (1.5) Verbal Learning – delayed recall Baseline, Mean (SD) G1: 5.9 (2.3) G2: 5.5 (2.0) After Treatment G1: 6.0 (2.6) G2: 4.8 (3.1) Rey Complex Figure – copy Baseline, Mean (SD) G1: 32.9 (4.2) G2: 29.7 (7.4) After Treatment G1: 33.6 (2.2) G2: 29.2 (6.8) Rey Complex Figure – delayed recall Baseline, Mean (SD) G1: 16.0 (6.2) G2: 13.9 (7.2) After Treatment G1: 25.6 (7.4) G2: 13.1 (9.4) G1: vs. G2, p <0.01 Within groups, p <0.01 Trail-Making Test A Baseline, Mean (SD) G1: 65.7 (35.5) G2: 64.7 (23.5) After Treatment G1: 60.6 (39.4) G2: 65.9 (34.0) Trail-Making Test B Baseline, Mean (SD) G1: 147.8 (64.4) G2: 131.3 (50.1) After Treatment G1: 131.0 (68.0) G2: 107.8 (36.0) SDMT Baseline, Mean (SD) G1: 29.9 (12.0) G2: 29.3 (13.7) After Treatment G1: 34.0 (12.6) G2: 31.1 (14.0) Verbal Fluency – letter S Baseline, Mean (S) G1: 10.4 (3.8) G2: 11.6 (7.3) After Treatment G1: 12.9 (5.6) G2: 10.3 (6.1) Verbal Fluency – animals Baseline, Mean (SD) G1: 18.4 (6.3) G2: 16.3 (4.5) After Treatment G1: 19.8 (6.2) G2: 14.11 (3.1) G1: vs. G2, p < 0.05 Other Yes “Both treatment forms were generally well tolerated. No serious adverse effects were reported. For 5 patients, rTMS was associated with severe local discomfort or pain, and 4 of them dropped out for that reason. The rest of the rTMS group experienced no or only slight inconvenience. Both groups revealed declining scores during the treatment period. The statistical analyses controlled for several essential variables( data not shown)…None of the 2 methods were associated with cognitive adverse effects or serious adverse effects on the UKU rating scale. Adequate information Yes Attrition Overall, % 30 At end of treatment, % G1: 33.3 G2: 26.7 At end of followup, % G1: NR G2: NR Withdrawals due to efficacy, % G1: NR G2: NR Withdrawals due to adverse events, % G1: NR G2: NR Other Withdrawal due to Discomfort at the stimulus site, % (n): G1: 16.7 (5) G2: 0 (0) Withdrawal due to serious deterioration, % (n): G1: 10 (3) G2: 3 (1) Withdrawal due to somatic disease, % (n): G1: 3 (1) G2: 0 (0) Withdrawal due to Commotio cerebri, % (n): G1: 0 (0) G2: 3 (1) Withdrawal for unknown reasons, % (n): G1: 0 (0) G2: 3 (1) Adherence/ compliance None reported
Author, Year McLoughlin et al., 2007^7^ Eranti et al., 2007^8^ Knapp et al., 2008^9^ Country, setting UK, South London and Maudsley NHS Trust and Pembury Hospital inInvicta Mental Health Trust in Kent, 65.2% were inpatients Funding National Health Service Research and Development, National Coordinating Centre for Health Technology Assessment (NCCHTA) (98/11/04); byGuy's and St. Thomas's Charitable Foundation (R001126); and by a 2003 Ritter Independent Investigator Award from National Alliance for Research on Schizophrenia and Depression. Research Objective To assess clinical effectiveness of rTMS vs. ECT for treating major depressive episodes in patients referred for ECT Quality Rating Good | Study design RCT- pragmatic and single blinded (raters) Type of analysis m-ITT N 46 Duration Primary endpoint at 3 weeks for rTMS and at clinicians discretion for ECT, additional follow-up at 6 months Interventions G1: ECT G2: rTMS Medication Allowed Patients continued their usual medical care and stable psychotropic medications were allowed (i.e. SSRIS, TCAs, Venlafaxine, Mirtazapine, Lithium, Anticonvulsant mood stabilizers, Benzodiazepines, Antipsychotics, Zopiclone, L-Tryptophan) Strategy Augmentation Parameters rTMS; - Frequency (Hz): 10; - Motor threshold (%):110; - Number of trains: 20; - Length of train (seconds): 5; - Inter-train interval: 55; - Pulses per session: 1000; - Total number of sessions:15; ECT:; - % receiving bilateral: 82; - Intensity: 1.5 × ST for bilateral frontotemporal ECT and 2.5 × ST for right unilateral ECT; - Number of sessions (range, mean, SD): range = 2-10, mean = 6.3, SD = 2.5 | TRD definition; - All patients referred for ECT:; - No failure required; Tier 3 Inclusion criteria; - Right handed patients; - more than 18 years old; - refered for ECT due to major depressive episode; Exclusion criteria; - Inability to have rTMS because of metallic implants or foreign bodies; - History of seizures; - Substance misuse in previous 6 months; - Being medically unfit for general anesthesia or ECT:; - ECT or rTMS in previous 6 months,; - Dementia or other axis I diagnosis; - Inability or refusal to provide informed consent. | Treatment Failure Mean failed trials G1: 2.5 (1.4) G2: 2.4 (1.0) Polarity, % MDD G1: 91.67 G2: 90.91 Bipolar G1: 8.33% G2: 9.09 % Age, mean yrs G1: 63.6 G2: 68.3 Sex, % females G1: 67.7 G2: 72.7 Right handed, % Overall: 100% HAM-D 17 Baseline n G1: 22 G2: 24 Baseline score, mean (SD) G1: 24.8 (5.0) G2: 23.9 (7.0) BDI: Baseline score, mean (SD) G1: 36 (8.7) G2: 37.8 (10.5) | HAM-D 17 Analyzed n G1: 22 G2: 23 Endpoint score, mean (SD) End of treatment G1: 10.7 G2: 18.5 P = 0.002, effect size of 1.44 Follow-up at 6 months G1: NR G2: NR P = 0.93 Change, mean (SD) End of treatment G1: -14.1 G2: -5.4 P = 0.017 Responders, n End of treatment G1: 13 (59.1%) G2: 4 (17.4%) P = 0.005 Remitters, n HAM-D ≤ 8 End ot treatment G1: 13 (59.1%) G2: 4 (17.4%) P = 0.005 Follow-up at 6 months* G1: 6 (27.4%) G2: 2 (8.7%) *only 12 ECT remitters followed after End of txt BDI Endpoint score, mean (SD) NR P = 0.01 effect size=0.9 Change, mean (SD) NR Group × time, P = 0.25 Responders, n NR Remitters, n NR | Quality of Life SF-36 mental health component score Baseline n G1: 24 G2: 22 Baseline score, mean (SD) G1: 48.9 (12.6) G2: 42.7 (7.5) Other: QALYs Six month QALY gain, mean (SD) G1: 0.0300 (0.053) G2: 0.0297 (0.056) (QALYs were derived using SF-36 data). At six month follow-up, service use data were collected on 28 pts (10-ECT and 18-rTMS). Patients responded much better to ECT than to rTMS by the end of the allocated treatment course. The differential QALY gain of treatment with rTMS over ECT was 0.0003 (p = 0.987). This suggests that treatment by rTMS does not provide any additional gains in quality of life over ECT over a 6-month period. The lack of a statistically significant difference in QALY gain between the two groups may reflect lack of difference in HRSD scores between groups at 6 months. Adverse Events NR Neuropsychological or executive functioning Predefined CAMCOG Attention and orientation subscale (max = 17): ECT baseline 12.8 (3.2), end of treatment 13.9 (3.6), 6mos 13.9 (3.5) rTMS baseline 14.7 (3.0) end of treatment 13.5 (3.3) FU6mos 13.4 (3.8), P = 0.004 No significant differences for rest of CAMCOG subscales (verbal fluency, anterograde memory, and retrograde memory) MMSE Baseline score, mean (SD) G1: 24.3 (3.6) G2: 25.7 (3.9) Score at 6 months, mean (SD) G1: 25.4 (5.3) G2: 24.7 (4.8) Endpoint score, mean (SD) G1: 25.6 (3.9) G2: 24.4 (5.3) Change, mean (SD): G1: 1.3 G2: -1.3 P < 0.08 No significant differences on the Columbia ECT Subjective Side Effects Schedule for self-reported cognitive side effects. Attrition Overall to end of treatment 6/46, at 6 months 9/46 At end of treatment, % G1: 6/24 G2: 0 At end of follow-up, % NR Withdrawals due to efficacy, % G1: 5/24 G2: 0 Withdrawals due to adverse events, % 0 Adherence/ compliance NR
Author, Year O'Connor, 2003^64^ Country, setting United States, University Hospital, inpatient vs. outpatient population not clearly reported Funding NIH/NIMH and a NARSAD grant Research Objective Two procedures for treating major depressive disorder were compared with regard to their respective effects on mood and cognition Quality Rating Poor | Study design Observational Type of analysis Completers N 28 Duration; - Primary outcome at end of treatment (ECT applied for 2 to 4 weeks and rTMS a period of 2 weeks).; - Patients assessed for follow-up 2 weeks post txt; Medications allowed rTMS patients completed a washout of all psychotropic medications while ECT continued all medications Strategy Switch strategy for rTMS and augment or add-on strategy for ECT group Interventions G1: ECT G2: rTMS Parameters ECT; - % receiving bilateral:0; - Intensity: 2.5 times seizure threshold; - Number of sessions (range, mean, SD): 6-12,; rTMS; - Frequency (Hz):10; - Motor threshold (%): 90; - Number of trains: 20; - Length of train (seconds): 8; - Inter-train interval: 24; - Pulses per session: 1600; - Total number of sessions:5/wk over 2wks | TRD definition; - Patients referred for ECT; - AD failures not required; Tier 3 Inclusion criteria; - Met criteria for MDD; - HRSD > 18; Exclusion criteria; - Psychosis, acute suicidality, other current Axis I diagnoses in DSM IV; - known CNS pathology, pacemakers, electronic or metallic implants, severe cardiac pathology; - personal or first degree family history of a seizure disorder; - inability to give informed consent | Treatment Failure Mean failed trials NR Polarity, % 100% MDD Age, mean yrs G1: 48.4+/- 12.0 G2: 51.2 +/- 12.2 HAM-D Baseline n Completers G1: 14 G2: 14 Baseline score, mean (SD) G1: 38.07 (8.1) G2: 29.3 (4.9) P = 0.001 Wechsler Memory Scale-III (WMS-III)-Letter Number Sequencing subtest Baseline n G1: 14 G2: 14 Baseline score, mean (SD) G1: 10.92 (2.49) G2: 10.42 (3.0) | HAM-D Endpoint score, mean (SD) End of treatment G1: 15.3 (11.7) G2: 25.6 (7.7) Follow-up 2 weeks G1: 20.4 (9.5) G2: 24.8 (9.5) Change, mean (SD) End of treatment G1: -23.7 G2: -3.73 Group × time P < 0.01 Responders, n G1: NR G2: 0 Remitters, n G1: NR G2: 100% Other Validated measure Yes Wechsler Memory Scale-III (WMS-III)-Letter Number Sequencing subtest Endpoint score, mean (SD) G1: 9.23 (1.83) G2: 10.71 (3.83) Change, mean (SD) At two weeks ECT scores on LN based on completers per protocol (n=13). ECT pts did not demonstrate a significant change in LN performance compared directly with2 week follow-up results (P > 0.05) No significant interaction between treatment sessions and groups with respect to LN (P > 0.05) | Quality of Life Adverse Events NR Neuropsychological or executive functioning Rey Auditory Verbal Learning Test-RAVLT (15 item word list to test new learning) Baseline n G1: 14 G2: 14 Baseline score, mean (SD) G1: 43.78 (11.07) G2: 43.71 (12.09) Endpoint score, mean (SD) G1: 29.14 (7.93) G2: 43.00 (10.00) Change, mean (SD) G1: 46.92 (10.80)/ Difference between baseline acquisition and performance on acquisition task during 2-wk f/u session was not significant: P > 0.05 G2: 44.07 (10.43) RAVLT, Acquisition, mean (SD) Baseline: ECT 43.78 (11.07) vs. rTMS 43.71 (12.09). End of treatment: ECT 29.14 (7.93) vs. rTMS 43.00 (10.09) P < 0.01. Two weeks later: ECT 46.92 (10.80) vs. rTMS 44.07 (10.43) P > 0.05. RAVLT, Retention,(15-item word list after a 20-minute delay interval), mean (SD) Baseline ECT 8.07 (4.49) words vs. rTMS 9.76 (3.08) End of treatment ECT 2.14 ( 1.99) vs. rTMS 8.23 (2.80) Two weeks later, ECT 8.92 (4.14) vs. rTMS 8.31 (4.07). Transient News Events Test (TNET-measure of retrograde memory) Baseline n G1: 14 G2: 14 Baseline score, mean (SD) G1: 64.30 (19.40) G2: 55.62 (18.12) Endpoint score, mean (SD) G1: 39.10 (13,.21) G2: 57.81 (18.33) Change, mean (SD) G1: 59.20 (20.67) G2: 61.54 (19.12) Other Main-effect-of-group (P > 0.05). There was evidence of a significant interaction b/t txt grp and txt session: P < 0.001. Cognitive function/memory impairment reported as primary outcome measures. MMSE NR Attrition Overall, % No attrition At end of treatment, % NR At end of follow-up, % NR Withdrawals due to efficacy, % 0 Withdrawals due to adverse events, % 0 Adherence/ compliance NR

Evidence Table 39 KQ 4. Adherence: Tier 3 (rTMS vs. sham—MDD/Bipolar)

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Bortolomasi et al., 2006^34^ Country, setting Italy, single center, inpatient vs. outpatient NR Funding Not reported Research Objective To investigate outcome of depressed patients treated for 1 month with high frequency rTMS onleft frontal lobe at long time periods Quality Rating Fair | Study design RCT Type of analysis Cannot tell, all reported patients included in analysis N 19 Duration Active: 5* days Follow-up: 1, 4 and 12 weeks, co -primary endpoints HAM-D and BDI *duration of txt is unclear in article Interventions G1: rTMS G2: Sham Medications allowed Patients continued their (failed) ADs and no medications changes were allowed (5.3% were not taking medications at study entry) Strategy Augmentation Allowed to continue on failed SSRIs (63.2%) and TCAs (26.3%), No meds (5.3%) Parameters rTMS; - Frequency (Hz):20; - Motor threshold (%): 90; - Number of trains: 20; - Length of train (seconds): 2; - Inter-train interval: 60; - Pulses per session: 800; - Total number of sessions: 5/wk; - Circular coil; Sham; - Stimulation coil was placed perpendicular tothe scalp surface without direct contact. Coil position was fixed for all TMS sessions, and stimulation at this site evoked minimal motor activity | TRD definition; - Drug resistance (not defined); - Not required or not specified to be in current episode; Tier 3 Inclusion criteria; - DSM-IV clinical criteria for major depression, right-handed, normal neurological examinations; Exclusion criteria; - Hx of brain trauma or seizure disorder; - Pacemakers, mobile metal implants or implanted medication pumps | Treatment Failure Mean failed trials NR Polarity, % Unipolar G1: 83.3 G2: 85.7 Bipolar G1: 16.7 G2: 14.3 Age, mean yrs G1: range 45-56 G2: range 44-53 Overall: 55.6 Sex, % females G1: 58 G2: 57 Race, % white NR Right handed, % Overall: 100 Groups similar at baseline Yes Tier HAM-D 24 Baseline n G1: 12 G2: 7 Baseline score, mean (SD) G1: 25.17 G2: NR | HAM-D 24 Endpoint score, mean (SD) At week 1 G1: 11.33 G2: 18.29 At week 4 G1: 11.42 G2: 19.14 At week 12 NR Change, mean (SD) At week 1 G1: -13.84 G2: NR P = NR, significant Group × time at wk 2 and 4, P < 0.05 At week 4 G1: -13.75 G2: NR At week 12 NR IG1: rTMS G2: Sham Baseline n G1: 12 G2: 7 Baseline score, mean (SD) G1: 25.42 G2: NR Endpoint score, mean (SD) At week 1 G1: 12.25 G2: 22.43 At week 4 G1: 11.67 G2: 24.57 Change, mean (SD) At week 1 G1: 13.17 G2: NR At week 4 G1: 13.75 G2: NR | Quality of Life NR Adverse Events No adverse effects were reported in either group, except for mild cephalgia by three patients treated with anti-inflammatory drugs Headache, % 3 patients reported mild headaches after treatment All rTMS patients referred to marked drowsiness for several hours immediately following. Six patients referred to subjective improvement of sleep after first stimulation session. Patients treated with sham condition did not report any symptoms related to drowsiness or sleep. 3 patients reported mild headaches after treatment Attrition Adherence/ compliance NR
Author, Year George et al., 1997^35^ Country, setting USA, outpatient setting Funding NARSAD, Ted and Vada Stlanley Foundation Research Objective To test hypothesis: daily left prefrontal rTMS has antidepressant effects Quality Rating Fair | Study design RCT, crossover Type of analysis ITT N 12 Duration 4 wk (2 wk intervention, 2 wk. follow-up) Primary outcome: Change in HAM-D after 2wks active txt Interventions G1: rTMS G2: sham stimulation Medications Allowed ADs tapered for 9, 3 partial responders continued their medication Strategy Mixed-within group differences Parameters rTMS; - Frequency (Hz):20; - Motor threshold (%): 80; - Number of trains: 20; - Length of train (seconds): 2; - Inter-train interval: NR; - Pulses per session:; - Total number of sessions: 5/wk for a total of 20 per patient; Sham:; - Same as above but angled at 45 degrees from skull | TRD definition; - Implied TRD, all patients had completed 1 or more medication trials but were depressed at study entry; - Not required or not specified to be in current episode; Tier 3 Inclusion criteria; - DSM-IV criteria for current MDD; - right-handed; Exclusion criteria; - Pts w abnormalities on general & neurological exam, urine drug screen, HIV test, MRI scan of head),; - Pacemakers; - H/O seizures; - H/O major head trauma | Treatment Failure Number of previous AD medications Overall: 13.4 Polarity, % Unipolar Overall: 91.7 Bipolar II Overall: 8.3 Age, mean yrs Overall: 41.8 (12.4) Sex, % females Overall: 91.7 Right handed, % Overall: 100 HAM-D 21 Baseline n G1: 12 G2: 12 Baseline score, mean (SD) Overall: 28.5 (4.2) | HAM-D 21 G1: rTMS G2: sham stimulation Change, mean (SD) At 2 weeks G1: -5.25 G2: +3.33 P < 0.03 | Quality of Life NR Adverse Events Headache, % G1: 4/12 G2: NR Suicidality, % G1: 0 G2: Sham: 1/12 Seizures: None Unexpected side effects: None Headaches NR by active v. sham Memory or Attention: None Attrition Overall: 0 Adherence/ compliance N

Evidence Table 40 KQ 5: Efficacy and harms for patient subpopulations

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Jorge et al., 2008^65^ Experiment 1 Country, setting USA, university hospital, outpatients and inpatients Funding NIMH Research Objective To assess efficacy and safety of rTMS to treat vascular depression Quality Rating Fair | Study design RCT Type of analysis m-ITT N 30 Duration 3 weeks Interventions G1: rTMS G2: Sham Medications Allowed None, all antidepressants discontinued Parameters rTMS; - Location of stimuli Left DLPC; - Frequency 10 Hz; - Intensity motor threshold. 110%; - Pulses per session - 20 trains per day, seperated by 1 minute pauses total 12000 pulses; - Number of sessions 10 in 10 days; Sham stimulation performed using a specially designed coil that looks exactly likestandard stimulating coil but generates a small localized field that drops off very fast, producing a scalp sensation without actual cortical stimulation Strategy Switch | TRD definition; - 1+ failed trials at an adequate dose; - Required to be in current episode; Tier 2 Inclusion criteria; - Onset of major depressive disorder (as diagnosed by DSM-IV criteria) at age 50 years or older; - history of subcortical stroke and/or at least 3 offollowing cardiovascular risk factors: arterial hypertension, diabetes mellitus, obesity, hyperlipidemia, and smoking; Exclusion criteria; - Severe heart or respiratory failure, renal or hepatic failure, oroccurrence of an ongoing neoplastic process, neurodegenerative disorders such as idiopathic Parkinson disease or probable Alzheimer disease; - patients with clinical evidence of dementia, actively suicidal, prominent psychotic features, or with comorbid alcohol or other drug abuse,; - prior occurrence of induced seizures, major head trauma, and a history of epilepsy, metal inskull, cranial cavity, or brain parenchyma,; - cardiac pacemaker, an implanted defibrillator, or a medication pump. | Subgroups Age 50+ Baseline N G1: 15 G2: 15 Treatment Failure Mean failed trials NR Polarity, % All pts met criteria for MDD in current episode 20% only met criteria for minor depression at study entry Age, mean yrs G1: 62.9 G2: 66.1 Sex, % females G1: 40 G2: 53 HAM-D Baseline score, mean (SD) G1: 19.5 (5.8) G2: 19.9 (5.4) | HAM-D 17 Endpoint score, mean (SD) NR Change, mean (SD) G1: 33.1% G2: 13.6% P = 0.04 Responders, n G1: 5 (33.3%) G2: 1 (6.7%) P = 0.08 Remitters, n HAM-D17< 8 and did not meet criteria for major or minor depression G1: 2 (13.3%) G2: 1 (6.7%) P = 0.5 | Quality of Life NR Adverse Events Overall, % NR Amnesia, % NR Cardiovascular adverse events, % NR Cognitive impairment, % NR Dizziness, % NR Headache, % G1: 33 G2: 27 Insomnia, % NR Post op complications, % NR Somnolence, % NR Suicidality, % NR Additional Comments TCD-12K vs. Sham Local pain 7 vs. 7 Local discomfort 27 vs. 33 Anxiety 13 vs. 0 “There were no significant differences betweenactive and sham stimulation groups infrequency of headaches or local discomfort. As expected, none ofpatients experienced a seizure. In addition, headaches were mild and responded in all cases to low doses of common analgesics.”; - Local pain 1 (7) vs. 1 (7); - Headaches 5 (33) vs. 4 (27); - Local discomfort 4 (27) vs. 5 (33); - Anxiety 2 (13) vs. 0; Neuropsychological or executive functioning Yes Measures, Results Variable Stimulation Group, Mean (SD) Scores P Value TCD-12K vs. Sham / TCD-18K vs. Sham Baseline values MMSE score 28.1 (1.6) vs. 26.9 (2.8) / 28.2 (1.4) vs. 28.6 (1.7) P = 0.61 RAVLT trials 1-5, score 42.1 (11.3) vs. 36.2 (12.4) / 41.7 (10.1) vs. 44.2 (9.6) P = 0.34 RAVLT delayed recall, score 7.6 (4.1) vs. 5.4 (2.4) / 7.5 (3.8) vs. 8.2 (3.3) P = 0.16 Trail Making Test B, s 124.8 (67.6) vs. 117.0 (58.7) / 99.5 (59.4) vs. 106.8 (63.0) P = 0.24 Stroop Color and Word Test, interference 29.7 (8.3) vs. 29.4 (11.7) / 33.5 (9.2) vs. 30.3 (10.0) P = 0.46 COWAT score 38.5 (14.0) vs. 27.7 (9.9) / 35.3 (11.4) vs. 39.6 (12.9) P = 0.08 Compared with sham stimulation, active rTMS at TCD-12K and TCD-18K was not associated with significant changes in ADLs as measured byFunctional Independence Measure or in most neuropsychological tests assessing memory and executive functions. However, after controlling for baseline Trail Making Test B time, patients receiving active rTMS had significantly decreased (ie, improved) Trail Making Test B times compared with patients receiving sham stimulation, forTCD-12K group (F1=7.7; P = 0.01) and TCD-18K group (F1=4.9; P = 0.03). No significant differences in Trail Making Test B times between responders and nonresponders, suggesting this effect was independent of mood. Predefined No MMSE Baseline n G1: 15 G2: 15 Baseline score, mean (SD) G1: 28.1 (1.6) G2: 26.9 (2.8) Endpoint score, mean (SD) NR Change, mean (SD) NR Other “There were no significant differences betweenactive and sham stimulation groups infrequency of headaches or local discomfort. As expected, none of patients experienced a seizure. In addition, headaches were mild and responded in all cases to low doses of common analgesics.” Local pain 1 (7) vs. 1 (7) Headaches 5 (33) vs. 4 (27) Local discomfort 4 (27) vs. 5 (33) Anxiety 2 (13) vs. 0 Adequate information No Attrition Overall, %; - 5 dropped out before first stimulation = 5%; - Did not report if it was from experiment 1 or 2; - No reported attrition after first stimulation.; At end of treatment, % 0 At end of followup, % 0 Withdrawals due to efficacy, % 0 Withdrawals due to adverse events, % 0 Other 5 patients withdrew before stimulation began Adherence/ compliance NR
Author, Year Jorge et al., 2004^66^ Country, setting USA, single center, outpatients Funding Charles A Dana Foundation Grant Research Objective To test hypothesis - high frequency rTMS ofleft dorsolateral prefrontal cortex would produce a significant reduction of depressive symptoms without affecting cognitive status of patients Quality Rating Fair | Study design RCT Type of analysis ITT N 20 Duration Active: 2 weeks treatment with primary outcomes assessed at 1 week post rTMS txt. Interventions G1: rTMS G2: Sham Medications Allowed All AD tapered. No other drugs reported Strategy Switch Parameters rTMS; - Location of stimuli LDLPFC; - Frequency 10 Hz; - Intensity motor threshold. 110%; - Pulses per session - 1600 (32 trains); - Number of sessions 10 over 2 weeks | TRD definition; - 2+ failed adequate trials (adequacy defined by ATHF); - Not required or not specified to be in current episode; Tier 1 Inclusion criteria; - Patients that had had a stroke and suffered from depression; Exclusion criteria; - Presence of severe systemic disease or an ongoing neoplasia; - Neurodegenerative disorders such as Parkinson disease or Alzheimer disease; - Clinical evidence of dementia (MMSE scores less than 23) aphasic patients with severe language comprehension deficits actively suicidal or who presented with prominent psychotic features or a bipolar course; - Evidence of alcohol or drug abuse during past 12 months; - Prior occurrence of induced seizures, major head trauma; - History of idiopathic epilepsy; metal in skull, cranial cavity, or brain parenchyma; - Cardiac pacemaker, an implanted defibrillator, or intracardiac lines | Subgroups Stroke induced depression Treatment Failure Mean failed trials, n (SD) G1: 3.8 G2: 3.8 Polarity, % 100% diagnosis of depression due to stroke 85% MDD 15% Minor Depression Age, mean yrs G1: 63.1 G2: 66.5 Sex, % females G1: 40 G2: 50 HAM-D 17 Baseline n G1: 10 G2: 10 Baseline score, mean (SD) G1: 20.1 (6.7) G2: 20.8 (6.0) | HAM-D 17 Endpoint score, mean (SD) G1: 12.8 G2: NR Change, mean % At week 3 G1: -38% (-7.3 pts) G2: -13% P < 0.006 Responders, n G1: 3 (30%) G2: 0 (0%) P = NS Remitters, n G1: 1 (10%) G2: 0 (0%) P = NS | Quality of Life NR Adverse Events Overall, % G1: NR Amnesia, % G1: NR Cardiovascular adverse events, % G1: NR Cognitive impairment, % G1: NR Dizziness, % G1: NR Headache, % G1: 30% Insomnia, % G1: 5% Post op complications, % G1: NR Somnolence, % G1: NR Suicidality, % G1: NR; - Transient headaches (six patients) relieved with low doses of acetaminophen, local discomfort at site of stimulation usually produced by tightness of stimulation cap (five patients), and an exacerbation of initial insomnia observed in one patient; - No significant differences infrequency of adverse events betweenactive andsham rTMS groups; - No patients with seizures or propagation of cortical excitability toipsilateral motor cortex; Neuropsychological or executive functioning Yes Measures, Results; - Neuropsychological variable at end point - mean (SD); - MMSE Scores 27.4 (3.0) vs. 26.5 (1.7); - RAVLT Scores, (delayed recall) 6.0 (3.2) vs. 5.2 (2.1); - COWAT Scores 36.0 (13.7) vs. 25.5 (6.5); - Trail Making Test B 144.4 (72.7) vs. 146.8 (62.4); - BNT Scores 26.8 (3.4) vs. 24.8 (3.9); Predefined Yes MMSE Baseline n G1: 10 G2: 10 Baseline score, mean (SD) G1: 25.9 G2: 26.4 Endpoint score, mean (SD) G1: 27.4 (3.0) G2: 26.5 (1.7) Change, mean (SD) G1: +1.5 (1.3) G2: +0.1 (2.4) Other Mann–Whitney x-squared 1.8, df = 1, P = 0.18 Adequate information No Attrition Overall, % 0 At end of treatment, % 0 At end of follow up, % 0 Withdrawals due to efficacy, % 0 Withdrawals due to adverse events, % 0 Other NR Adherence/ compliance NR

Evidence Table 41 KQ 6: Quality of life

Study Citation, Country, Setting Funding, Research Objective | Study Design N Duration Comparison | Study Sample Inclusion, Exclusion Criteria | Baseline Characteristics | Remission/Response | Quality of Life Adverse Events Attrition
Author, Year Harley, 2008^36^ Country, setting United States, university clinics, outpatient psychiatric Funding Kaplan Fellowship Award Grant through Harvard Medical School Research Objective To assess feasibility and potential utility of a Dialectical Behavior Therapy(DBT)-based skills training group for TRD Quality Rating Fair | Study design RCT Type of analysis Completers N 24 Duration Primary outcome after 16 weeks of active txt Follow up: 6 months Interventions G1: DBT-based skills training G2: Wait-list Control Medications Allowed Patients continued antidepressant therapy Strategy Augmentation Parameters; - Type of therapy: Dialectical Behavior Therapy(DBT)-based skills training; - Method: Group; - Number of sessions/week:1; - Total number of sessions:16; G2: Wait list | TRD definition; - 1+ failed medications (6+ weeks at “standard effective dose”); - Not required or not specified to be in current episode; Tier 2 Inclusion criteria; - 18-65 years with a principal diagnosis of MDD; - Established treatment relationship with a psychiatrist at MGH or in larger community.; - Stabalized on an adequate dose of antidepressant medication before entering study.; Exclusion criteria; - Borderline personaliy disorder, bipolar disorder, psychotic spectrum disorders, active substance abuse or dependence, mental retardation, or pervasive developmental disorder.; - Active suicidality requiring more intensive levels of care; - Severe or unstable medical conditions; - Previous or current CBT experience. | Baseline N G1: 13 G2: 11 Treatment Failure Mean failed trials NR Polarity, % MDD Overall: 100 Age, mean yrs Overall: 41.8 Sex, % females Overall: 75 Race, % white Overall: 83 HAM-D 17 Baseline score, mean (SD) G1: 16.15 (4.47) G2: 18.64 (4.72) P = NS BDI Baseline score, mean (SD) G1: 27.31 (8.83) G2: 27.44 (11.66) P = NS | HAM-D 17 Analyzed n G1: 10 G2: 9 Endpoint score, mean (SD) Completers analysis, 16 weeks G1: 11.30 (5.3) G2: 17.11 (6.23) Change, mean (SD) Completers, 16 weeks G1: -5.6 G2: -1.78 P < 0.05 Remitters, n Completers per protocol analysis, 16 weeks G1: 3 (23%*) G2: 0 (0%*) P = NR BDI Endpoint score, mean (SD) At Week 16, completers per protocol G1: 15.10 (12.13) G2: 25.89 (16.30) Change, mean (SD) G1: -12.80 G2: -1.55 P < 0.01 | Quality of Life Lifework-The Range of Impaired Functioning Tool (LIFE-RIFT) Baseline n G1: 10 G2: 9 Baseline score, mean (SD) G1: 4.00 (0.94) G2: 3.44 (1.24) Endpoint score, mean (SD) G1: 2.70 (1.34) G2: 3.11 (1.69) Change, mean (SD) G1: -1.3 G2: -0.33 P = NS Social Adjustment Scale-Self-Report (SAS-SR) work subscale Baseline n G1: 10 G2: 9 Baseline score, mean (SD) G1: 82.50 (21.21) G2: 69.22 (17.95) Endpoint score, mean (SD) G1: 65.70 (19.27) G2: 69.56 (17.66) Change, mean (SD) G1: -16.80 G2: 0.34 P < 0.05 Adverse Events NR MMSE NR Attrition Overall, %: 21 At end of treatment, % G1:23 G2:18 At end of followup, % G1:20 G2: NR Withdrawals due to efficacy, % G1: 8 G2: 0 Withdrawals due to adverse events, % 0 Other 5 participants (3 groups, 2 wait-lists) did not complete study. One group participant dropped out because of difficulty finding childcare another discontinued treatment due to a work schedule conflict, and third decided group was not a good fit. One wait-list participant moved and could not continue instudy and a medical problem preventedsecond from continuing. Adherence/ compliance Compliance Participants completed a weekly check-in form asking about medication compliance overpreceding month.19 participants who completed study reported that they had been largely medication compliant—11 reported that they had taken their medication as directed every day and 8 reported that they had forgotten a medication dose between 1 to 4 times inprevious month.
Author, Year Fitzgerald et al., 2003^15^ Country, setting Australia 2 general psychiatric services, outpatients Funding National Health and Medical Research Council and a grant fromStanley Medical Research Institute Research Objective To evaluate efficacy of HFL-TMS and LFR-TMS in treatment-resistant depression and compared with a sham-treated control group Quality Rating Good | Study design RCT Type of analysis ITT N 60 Tier 1 Duration Primary endpoint after 2 weeks of txt, after which pts with <20% reduction in MADRS could cross over to the other active txt. Follow up assessment conducted at 2 weeks post txt. Interventions G1: High Frequency rTMS G2: Low Frequency rTMS G3: Sham Medications Allowed 46 patients continued (failed) AD medication while others were not on a med at study entry. Patients allowed mood stabilizers and antipsychotics Strategy Augmentation Parameters rTMS LowFrequency (Hz):1; - Motor threshold (%): 100; - Number of trains: 60; - Length of train (seconds): 5; - Inter-train interval:60; - Pulses per session: 300; - Total number of sessions: 10 sessions daily, 5 days/week; rTMS High; - Frequency (Hz):10; - Motor threshold (%): 100; - Number of trains: 20; - Length of train (seconds): 5; - Inter-train interval: 25; - Pulses per session: 1000; - Total number of sessions: 10 sessions daily, 5 days/week; Sham rTMS; - Coil angled 45 degrees offhead for 10 sessions daily, 5 days/week | TRD definition; - Failed a minimum of 2 courses of antidepressant medications (6+ weeks); Not required or not specified to be in current episode Inclusion criteria; - DSM-IV diagnosis of Major Depression (included bipolar depression); Exclusion criteria; - Significant medical illnesses, neurologic disorders, or other Axis I psychiatric disorders | Treatment Failure Mean failed trials Overall (SD) 5.68 (3.40) Polarity, % Bipolar I G1: 5 G2: 5 G3: 20 Age, mean yrs G1: 42.2 G2: 45.55 G3: 49.15 Sex, % females G1: 40 G2: 35 G3: 55 Right handed, % G1: 90 G2: 100 G3: 85 BDI Baseline n G1: 20 G2: 20 G3: 20 Baseline score, mean (SD) G1: 33.15 (12.12) G2: 35.05 (9.25) G3: 32.30 (9.10) MADRS Baseline n G1: 20 G2: 20 G3: 20 Baseline score, mean (SD) G1: 36.05 (7.55) G2: 37.70 (8.36) G3: 35.75 (8.14) | BDI Endpoint score, mean (SD) At 2 weeks G1: 26.7 (11.9) G2: 27.2 (10.8) G3: 29.0 (8.7) Change, mean (SD) At 2 weeks G1:- 6.4 G2: -7.8 G3: -2.3 P = 0.03 MADRS Endpoint score, mean (SD) At 2 weeks G1: 30.8 (7.8) G2: 32.2 (9.0) G3: 35.4 (7.5) Change, mean; % change, (SD) At 2 weeks G1: -5.25; 13.5 % (16.7%) G2: -5.5; 15.0% (14.1%) G3: -0.35; 0.76% (16.2%) P = 0.004 G1: vs. G3, G2 vs. G3, P < 0.005 Responders, n 20% ≤ decrease At 2 weeks G1: 8 (40) G2: 7 (35) G3: 2 (10) P = 0.07 Responders, n 50% ≤ decrease At 2 weeks G1: 0 G2: 1 (5) G3: 0 P = NR CGI Endpoint score, mean (SD) NR P =.01 | Quality of Life GAF Global Assessment of Functioning Baseline n G1: 20 G2: 20 G3: 20 Baseline score, mean (SD) G1: 43.00 (6.76) G2: 43.55 (9.94) G3: 42.75 (7.15) Endpoint score, mean (SD) At 2 weeks G1: 45.2 (7.1) G2: 46.3 (8.5) G3: 42.5 (6.8) Change, mean (SD) At 2 weeks G1: 2.2 G2: 2.85 G3: 0.5 Overall group F56,2=2.6; P =.08; LFR-TMS vs sham: P = 0.03; and HFLTMS vs sham: P = 0.09 Quality of Life Overall group F56,2=2.6; P =.08; LFR-TMS vs sham: P = 0.03; and HFLTMS vs sham: P = 0.09 Adverse Events Dizziness, % G1: 5% G2: 5% G3: 0 G4: 3.3% Other: 0- 2wks:; - 7 (11%) of 60 patients reported site discomfort or pain during rTMS and 6 (10%) reported a headache after rTMS.; - Although there was no difference in incidence of these adverse effects (P =.08), patients inHFL-TMS group seemed to report more discomfort during procedure itself.; - Only 1 patient ( HFL-TMS group) reported persistence ofheadache for longer than 1 hour.; - Two patients (1 in each group) reported transient dizziness for a short time after treatment.; 2wks - 4 wks:; - One patient withdrew after 1 session of HFL-TMS treatment insingle-blind phase ofstudy owing to site pain.; - One bipolar patient, who had a successful response to LFR-TMS treatment, experienced a manic episode 10 days after completion of trial after ceasing treatment with valproate sodium; Neuropsychological or executive functioning; - No deterioration in performance was found in any cognitive measures in group as a whole or in analyses of patients who received HFL-TMS only LFR-TMS only, or both active treatment conditions; - Including all patients who underwent at least 1 type of active treatment, there was a significant improvement in performance onverbal paired associates (t50=−7.3; P < 0.001), verbal fluency (t48=−3.8; P < 0.001), and digit span forwards (t48=−1.8; P = 0.003) subscales;Personal Semantic Memory Schedule (t50=−2.4; P = 0.02); andAutobiographical Memory Schedule (t50=−1.9; P = 0.05).; - A similar pattern of improvements was seen for each oftreatment subgroups (HFL-TMS only, LFR-TMS only, or both active treatments).; - Changes in performance oncognitive measures did not correlate with changes in MADRS and Beck Depression Inventory scores acrosssame times.; MMSE NR Other Attrition Overall, % None in initial 2 week treatment phase At end of treatment, % 0 At end of followup, % NR But at least 28.3% did not continue on thru2nd 2 weeks Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % G1: 0 (1 during followup) G2: 0 (0 during followup) G3: 0 (0 during followup) Progression of patients through 2nd phase is very unclear Adherence/ compliance NR
Author, Year Rush et al., 2005^24^ Carpenter et al., 2004^25^ Country, setting US, multicente, outpatient psychiatric Funding Cyberonics, Inc. Research Objective To compare adjunctive VNS to sham in TRD patients Quality Rating Good | Study design RCT Type of analysis m-ITT/PP for efficacy, ITT for Aes N 235 Duration 10wks of stimulation Primary Outcome: HAM-D Response after 10wks txt Interventions G1: VNS G2: Sham Medications allowed pts allowed up to 5 antidepressants, mood stablizers, or other psychotropic medications Strategy Augmentation Parameters VNS: Frequency (Hz): 20 Pulse width (seconds): 500 μs; - On/Off cycle parameters: 30 sec on and 5 min off; - Duration of treatment:; Sham:; - Device implanted but not turned on | TRD definition; - TRD (2-6 failures verified by the ATHF, with failures in tw different drug classes); - Required to be in current episode; Tier 1 Inclusion criteria; - Current Major Depressive Episode (MDE) of 2+ yrs OR 4+ MDE in lifetime,; - age 18-80, HAM-D24>=20;; - bipolar pts had to also be resistant, intolerant of, or have contraindications to lithium; Exclusion criteria; - Atypical or psychotic features in any MDE; - current rapid cycling bipolar disorder, delerium, dementia, amnesia; - other cognitive disoder, suicidality; - risks related to surgical implantation | Treatment Failure Percent with 4-6 current episode failures G1: 46.5% G2: 40.0% Polarity, % Unipolar G1: 88.4 G2: 90.9 Bipolar I G1: 5.4 G2: 3.6 Bipolar II G1: 6.3 G2: 5.5 Age, mean yrs G1: 47.0 G2: 45.9 Sex, % females G1: 59 G2: 66 Race, % white G1: 97 G2: 96 HAM-D24 Baseline n G1: 119 G2: 116 Baseline score, mean (SD) G1: 28.8(5.3) G2: 29.7(5.2) MADRS Baseline score, mean (SD) G1: 31.4(6.3) G2: 31.9(6.3) IDS Baseline n G1: 112 (115 randomized) G2: 110 Baseline score, mean (SD) G1: 44.3(9.1) G2: 45.4(8.5) CGI-I Baseline n G1: 112 G2: 110 | HAM-D24 N analyzed G1: 112 G2: 110 Endpoint score, mean (SD) NR % change, mean (SD) G1: -16.3 (28.1) G2: -15.3 (25.5) P = 0.639 Responders, n G1: 17 (15.2%) G2: 11 (10.0%) P = 0.251 MADRS Endpoint score, mean (SD) NR % change, mean (SD) G1: -17.1 (31.2) G2: -12.4 (27.1) P = 0.208 Responders, n G1: 17 (15.2) G2: 12 (0.0) P = 0.378 IDS Endpoint score, mean (SD) NR % change, mean (SD) G1: 21.2 (25.4) G2: 16.3 (26.2) P = 0.158 Responders, n G1: 19 (17) G2: 8 (7.3) P = 0.032 Remitters, n NR CGI-I Endpoint score, mean (SD) NR Achieving 1 or 2 score, %(SD) G1: 13.9 G2: 11.8 VNS v. Sham, P = 0.648 | Quality of Life Medical Outcomes Study Short Form-36 (MOS-SF36) Baseline n G1: 112/ N=107 QOL analysis G2: 110/ N=107 QOL analysis Baseline score, mean (SD) NR Endpoint score, mean (SD) NR Change, mean (SD) G1: physical component: -0.9 (8.3); mental component: 5.0 (11.6) G2: physical component -1.6(8.4); mental component: 4.0(10.2) Other Physical component between VNS and sham: P = 0.480, Mental Component between VNS and sham: P = 0.406 Adverse Events Overall, % NR Cardiovascular adverse events, % G1: 5, palpitations 5 G2: 3 Other:–; - voice alteration: 68% v 38%; - cough increased: 29% v 9%; - dyspnea: 23% v 14%,; - dysphagia: 21% v 11%,; - neck pain: 21% v 10%,; - paresthesia: 16% v 10%,; - vomiting: 11% vs. 12%,; - laryngismus 11% v 2%,; - dyspepsia 10 v 5; - wound infection 8% v 2%,; - hypomania/mania (via Young Mania Scale): 1.7% (1pt with a prestudy dx of bipolar) v 0%; Overall SAEs 30, pts VNS: 13.4% (16/119). Sham: 12.1% (14/116) 12 events, involving 11 patients, were cases of worsening depression requiring hospitalization Cardiac SAEs during implantation: 1.7% v 0% COSTART used to code reported events Attrition Overall, % 1.3 (3/235) At end of treatment, % G1: 2.6 G2: 0 At end of followup, % NR Withdrawals due to efficacy, % NR Withdrawals due to adverse events, % G1: 2.6 G2: 0 9 pts had a protocol violation post randomization Adherence/ compliance NR

## References

1 Pridmore S. Substitution of rapid transcranial magnetic stimulation treatments for electroconvulsive therapy treatments in a course of electroconvulsive therapy. Depress Anxiety. 2000;12(3):118-23. [pmid: 11126185].
2 Rosa MA, Gattaz WF, Pascual-Leone A, et al. Comparison of repetitive transcranial magnetic stimulation and electroconvulsive therapy in unipolar non-psychotic refractory depression: a randomized, single-blind study. Int J Neuropsychopharmacol. 2006;9(6):667-76. [pmid: 16923322].
3 Grunhaus L, Schreiber S, Dolberg OT, et al. A randomized controlled comparison of electroconvulsive therapy and repetitive transcranial magnetic stimulation in severe and resistant nonpsychotic major depression. Biol Psychiatry. 2003:324-31. [pmid: 12586451].
4 Kocsis JH, Gelenberg AJ, Rothbaum BO, et al. Cognitive behavioral analysis system of psychotherapy and brief supportive psychotherapy for augmentation of antidepressant nonresponse in chronic depression: The REVAMP trial. Archives of General Psychiatry. US: American Medical Assn 2009:1178-88.
5 Chistyakov AV, Kaplan B, Rubichek O, et al. Effect of electroconvulsive therapy on cortical excitability in patients with major depression: a transcranial magnetic stimulation study. Clin Neurophysiol. 2005;116(2):386-92. [pmid: 15661116].
6 Hansen PE, Ravnkilde B, Videbech P, et al. Low-Frequency Repetitive Transcranial Magnetic Stimulation Inferior to Electroconvulsive Therapy in Treating Depression. J ECT. 2010/03/31 ed 2010
7 McLoughlin DM, Mogg A, Eranti S, et al. The clinical effectiveness and cost of repetitive transcranial magnetic stimulation versus electroconvulsive therapy in severe depression: a multicentre pragmatic randomised controlled trial and economic analysis. Health Technol Assess. 2007;11(24):1-54. [pmid: 17580003].
8 Eranti S, Mogg A, Pluck G, et al. A randomized, controlled trial with 6-month follow-up of repetitive transcranial magnetic stimulation and electroconvulsive therapy for severe depression. Am J Psychiatry. 2007;164(1):73-81. [pmid: 17202547].
9 Knapp M, Romeo R, Mogg A, et al. Cost-effectiveness of transcranial magnetic stimulation vs electroconvulsive therapy for severe depression: A multi-centre randomised controlled trial. Journal of Affective Disorders. 2008:273-85. [pmid: 18262655].
10 Avery DH, Holtzheimer PE, Fawaz W, et al. A controlled study of repetitive transcranial magnetic stimulation in medication-resistant major depression. Biol Psychiatry. 2006;59(2):187-94. [pmid: 16139808].
11 Avery DH, Holtzheimer PE, Fawaz W, et al. Transcranial magnetic stimulation reduces pain in patients with major depression: a sham-controlled study. J Nerv Ment Dis. 2007;195(5):378-81. [pmid: 17502802].
12 Bocchio-Chiavetto L, Miniussi C, Zanardini R, et al. 5-HTTLPR and BDNF Val66Met polymorphisms and response to rTMS treatment in drug resistant depression. Neurosci Lett. 2008;437(2):130-4. [pmid: 18450378].
13 Boutros NN, Gueorguieva R, Hoffman RE, et al. Lack of a therapeutic effect of a 2-week sub-threshold transcranial magnetic stimulation course for treatment-resistant depression. Psychiatry Research. 2002 Dec 2002;113(3):245-54.
14 Fitzgerald PB, Benitez J, de Castella A, et al. A randomized, controlled trial of sequential bilateral repetitive transcranial magnetic stimulation for treatment-resistant depression. Am J Psychiatry. 2006;163(1):88-94. [pmid: 16390894].
15 Fitzgerald PB, Brown TL, Marston NA, et al. Transcranial magnetic stimulation in the treatment of depression: a double-blind, placebo-controlled trial. Arch Gen Psychiatry. 2003;60(10):1002-8. [pmid: 14557145].
16 Garcia-Toro M, Mayol A, Arnillas H, et al. Modest adjunctive benefit with transcranial magnetic stimulation in medication-resistant depression. Journal of Affective Disorders. 2001 May 2001;64(2):271-5.
17 Garcia-Toro M, Salva J, Daumal J, et al. High (20-Hz) and low (1-Hz) frequency transcranial magnetic stimulation as adjuvant treatment in medication-resistant depression. Psychiatry Res. 2006;146(1):53-7. [pmid: 16356697].
18 George MS, Lisanby SH, Avery D, et al. Daily left prefrontal transcranial magnetic stimulation therapy for major depressive disorder: a sham-controlled randomized trial. Arch Gen Psychiatry. 2010/05/05 ed 2010:507-16.
19 Holtzheimer PE 3rd, Russo J, Claypoole KH, et al. Shorter duration of depressive episode may predict response to repetitive transcranial magnetic stimulation. Depress Anxiety. 2004;19(1):24-30. [pmid: 14978782].
20 Kauffmann CD, Cheema MA, Miller BE. Slow right prefrontal transcranial magnetic stimulation as a treatment for medication-resistant depression: a double-blind, placebo-controlled study. Depression and Anxiety. 2004;19(1):59-62. [pmid: 14978787].
21 Padberg F, Zwanzger P, Thoma H, et al. Repetitive transcranial magnetic stimulation (rTMS) in pharmacotherapy-refractory major depression: comparative study of fast, slow and sham rTMS. Psychiatry Res. 1999:163-71. [pmid: 10622338].
22 Pallanti S, Bernardi S, Di Rollo A, et al. Unilateral low frequency versus sequential bilateral repetitive transcranial magnetic stimulation: is simpler better for treatment of resistant depression? Neuroscience. 2010/02/11 ed 2010:323-8.
23 Pascual-Leone A, Rubio B, Pallardo F, et al. Rapid-rate transcranial magnetic stimulation of left dorsolateral prefrontal cortex in drug-resistant depression. Lancet. 1996;348(9022):233-7. [pmid: 8684201].
24 Rush AJ, Marangell LB, Sackeim HA, et al. Vagus nerve stimulation for treatment-resistant depression: a randomized, controlled acute phase trial. Biological Psychiatry. 2005 Sep 2005;58(5):347-54.
25 Carpenter LL, Moreno FA, Kling MA, et al. Effect of vagus nerve stimulation on cerebrospinal fluid monoamine metabolites, norepinephrine, and gamma-aminobutyric acid concentrations in depressed patients. Biological Psychiatry. 2004 Sep 2004;56(6):418-26.
26 Su T-P, Huang C-C, Wei IH. Add-On rTMS for medication-resistant depression: a randomized, double-blind, sham-controlled trial in Chinese patients. Journal of Clinical Psychiatry. 2005 Jul 2005;66(7):930-7.
27 Zheng H, Zhang L, Li L, et al. High-frequency rTMS treatment increases left prefrontal myo-inositol in young patients with treatment-resistant depression. Progress in Neuro-Psychopharmacology & Biological Psychiatry. Netherlands: Elsevier Science 2010:1189-95.
28 Berman RM, Narasimhan M, Sanacora G, et al. A randomized clinical trial of repetitive transcranial magnetic stimulation in the treatment of major depression. Biological Psychiatry. 2000 Feb 2000;47(4):332-7.
29 Manes F, Jorge R, Morcuende M, et al. A controlled study of repetitive transcranial magnetic stimulation as a treatment of depression in the elderly. International Psychogeriatrics. 2001 Jun 2001;13(2):225-31.
30 Moser DJ, Jorge RE, Manes F, et al. Improved executive functioning following repetitive transcranial magnetic stimulation. Neurology. 2002:1288-90. [pmid: 11971103].
31 O'Reardon JP, Solvason HB, Janicak PG, et al. Efficacy and safety of transcranial magnetic stimulation in the acute treatment of major depression: a multisite randomized controlled trial. Biol Psychiatry. 2007:1208-16. [pmid: 17573044].
32 Stern WM, Tormos JM, Press DZ, et al. Antidepressant effects of high and low frequency repetitive transcranial magnetic stimulation to the dorsolateral prefrontal cortex: a double-blind, randomized, placebo-controlled trial. J Neuropsychiatry Clin Neurosci. 2007;19(2):179-86. [pmid: 17431065].
33 Wiles NJ, Hollinghurst S, Mason V, et al. A randomized controlled trial of cognitive behavioural therapy as an adjunct to pharmacotherapy in primary care based patients with treatment resistant depression: A pilot study. Behavioural and Cognitive Psychotherapy. 2008 Jan 2008;36(1):21-33.
34 Bortolomasi M, Minelli A, Fuggetta G, et al. Long-lasting effects of high frequency repetitive transcranial magnetic stimulation in major depressed patients. Psychiatry Res. 2007;150(2):181-6. [pmid: 17303249].
35 George MS, Wassermann EM, Kimbrell TA, et al. Mood improvement following daily left prefrontal repetitive transcranial magnetic stimulation in patients with depression: a placebo-controlled crossover trial. Am J Psychiatry. 1997;154(12):1752-6. [pmid: 9396958].
36 Harley R, Sprich S, Safren S, et al. Adaptation of dialectical behavior therapy skills training group for treatment-resistant depression. J Nerv Ment Dis. 2008;196(2):136-43. [pmid: 18277222].
37 Möller AL, Hjaltason Ó, Ívarsson Ó, et al. The effects of repetitive transcranial magnetic stimulation on depressive symptoms and the P-sub-3-sub-0-sub-0 event-related potential. Nordic Journal of Psychiatry. 2006 2006;60(4):282-5.
38 Paykel ES, Scott J, Teasdale JD, et al. Prevention of relapse in residual depression by cognitive therapy. A controlled trial. Archives of General Psychiatry. 1999;56(9):829-35. [pmid: 12884889].
39 Kennedy N, Paykel ES. Treatment and response in refractory depression: results from a specialist affective disorders service. J Affect Disord. 2004;81(1):49-53. [pmid: 15183599].
40 West ED. Electric convulsion therapy in depression: a double-blind controlled trial. Br Med J (Clin Res Ed) 1981:355-7.
41 Bretlau LG, Lunde M, Lindberg L, et al. Repetitive transcranial magnetic stimulation (rTMS) in combination with escitalopram in patients with treatment-resistant major depression: a double-blind, randomised, sham-controlled trial. Pharmacopsychiatry. 2008:41-7. [pmid: 18311683].
42 Folkerts HW, Michael N, Tölle R, et al. Electroconvulsive therapy vs. paroxetine in treatment-resistant depression -- a randomized study. Acta Psychiatr Scand. 1997;96(5):334-42. [pmid: 9395150].
43 Moore RG, Blackburn I-M. Cognitive therapy in the treatment of non-responders to antidepressant medication: A controlled pilot study. Behavioural and Cognitive Psychotherapy. 1997 1997;25(3):251-9.
44 Thase ME, Friedman ES, Biggs MM, et al. Cognitive therapy versus medication in augmentation and switch strategies as second-step treatments: a STAR*D report. Am J Psychiatry. 2007:739-52. [pmid: 17475733].
45 Dannon PN, Dolberg OT, Schreiber S, et al. Three and six-month outcome following courses of either ECT or rTMS in a population of severely depressed individuals--preliminary report. Biol Psychiatry. 2002;51(8):687-90. [pmid: 11955470].
46 Berman RM, Marcus RN, Swanink R, et al. The efficacy and safety of aripiprazole as adjunctive therapy in major depressive disorder : A multicenter, randomized, double-blind, placebo-controlled study. Memphis, TN, ETATS-UNIS: Physicians Postgraduate Press 2007:11.
47 Berman RM, Fava M, Thase ME, et al. Aripiprazole augmentation in major depressive disorder: a double-blind, placebo-controlled study in patients with inadequate response to antidepressants. CNS Spectr. 2009/05/02 ed 2009:197-206.
48 Corya SA, Williamson D, Sanger TM, et al. A randomized, double-blind comparison of olanzapine/fluoxetine combination, olanzapine, fluoxetine, and venlafaxine in treatment-resistant depression. Depress Anxiety. 2006:364-72. [pmid: 16710853].
49 Fang Y, Yuan C, Xu Y, et al. Comparisons of the efficacy and tolerability of extended-release venlafaxine, mirtazapine, and paroxetine in treatment-resistant depression: A double-blind, randomized pilot study in a Chinese population. Journal of Clinical Psychopharmacology. US: Lippincott Williams & Wilkins 2010:357-64.
50 Fava M, Rush AJ, Wisniewski SR, et al. A comparison of mirtazapine and nortriptyline following two consecutive failed medication treatments for depressed outpatients: a STAR*D report. Am J Psychiatry. 2006:1161-72. [pmid: 16816220].
51 Mazeh D, Shahal B, Aviv A, et al. A randomized, single-blind, comparison of venlafaxine with paroxetine in elderly patients suffering from resistant depression. Int Clin Psychopharmacol. 2007:371-5. [pmid: 17917556].
52 Little JT, Kimbrell TA, Wassermann EM, et al. Cognitive effects of 1- and 20-hertz repetitive transcranial magnetic stimulation in depression: preliminary report. Neuropsychiatry Neuropsychol Behav Neurol. 2000;13(2):119-24. [pmid: 10780630].
53 Poirier MF, Boyer P. Venlafaxine and paroxetine in treatment-resistant depression. Double-blind, randomised comparison. Br J Psychiatry. 1999:12-6. [pmid: 10621762].
54 Shelton RC, Williamson DJ, Corya SA, et al. Olanzapine/fluoxetine combination for treatment-resistant depression: a controlled study of SSRI and nortriptyline resistance. J Clin Psychiatry. 2005:1289-97. [pmid: 16259543].
55 Thase ME, Corya SA, Osuntokun O, et al. A randomized, double-blind comparison of olanzapine/fluoxetine combination, olanzapine, and fluoxetine in treatment-resistant major depressive disorder. Journal of Clinical Psychiatry. US: Physicians Postgraduate Press 2007:224-36.
56 Janicak PG, Nahas Z, Lisanby SH, et al. Durability of acute tesponse to TMS in the treatment of major depression: relapse during a continuation pharmacotherapy extension study. Society for Biological Psychiatry Annual Meeting; 2007 May; San Diego, CA; 2007
57 Solvason HB, Husain M, Fitzgerald PB, et al. TMS in the acute treatment of major depression: Improvments in functional status and quality of life. Society of Bilogical Psychiatry Annual Meeting. San Diego, CA 2007
58 Janicak PG, Nahas Z, Lisanby SH, et al. Durability of clinical benefit with transcranial magnetic stimulation (TMS) in the treatment of pharmacoresistant major depression: Assessment of relapse during a 6-month, multisite, open-label study. Brain Stimulation. Netherlands: Elsevier Science 2010:187-99.
59 Scott J, Teasdale JD, Paykel ES, et al. Effects of cognitive therapy on psychological symptoms and social functioning in residual. British Journal of Psychiatry. 2000;177(NOV):440-6. [pmid: 11059998].
60 Scott J, Palmer S, Paykel E, et al. Use of cognitive therapy for relapse prevention in chronic depression. Cost-effectiveness study. Br J Psychiatry. 2003;182:221-7. [pmid: 12611785].
61 Paykel ES, Scott J, Cornwall PL, et al. Duration of relapse prevention after cognitive therapy in residual depression: follow-up of controlled trial. Psychol Med. 2005/04/22 ed 2005:59-68.
62 Grunhaus L, Dannon PN, Schreiber S, et al. Repetitive transcranial magnetic stimulation is as effective as electroconvulsive therapy in the treatment of nondelusional major depressive disorder: an open study. Biol Psychiatry. 2000;47(4):314-24. [pmid: 10686266].
63 Schulze-Rauschenbach SC, Harms U, Schlaepfer TE, et al. Distinctive neurocognitive effects of repetitive transcranial magnetic stimulation and electroconvulsive therapy in major depression. Br J Psychiatry. 2005;186:410-6. [pmid: 15863746].
64 O'Connor M, Brenninkmeyer C, Morgan A, et al. Relative effects of repetitive transcranial magnetic stimulation and electroconvulsive therapy on mood and memory: a neurocognitive risk-benefit analysis. Cogn Behav Neurol. 2003;16(2):118-27. [pmid: 12799598].
65 Jorge RE, Moser DJ, Acion L, et al. Treatment of vascular depression using repetitive transcranial magnetic stimulation. Arch Gen Psychiatry. 2008;65(3):268-76. [pmid: 18316673].
66 Jorge RE, Robinson RG, Tateno A, et al. Repetitive transcranial magnetic stimulation as treatment of poststroke depression: a preliminary study. Biol Psychiatry. 2004;55(4):398-405. [pmid: 14960293].