# Excluded Studies

## No or Wrong Comparison

1 Abbass AA. Intensiveshort-term dynamic psychotherapy of treatment-resistant depression: a pilot study. Depress Anxiety. 2006;23(7):449-52. [pmid: 16845654].
2 Abraham G, Milev R, Lazowski L, Jokic R, du Toit R, Lowe A. Repetitive transcranial magnetic stimulation for treatment of elderly patients with depression--An open label trial. Neuropsychiatric Disease and Treatment. 2007;3(6):919-24. [pmid: 19300628].
3 Abrams R, Swartz CM, Vedak C. Antidepressant effects of high-dose right unilateral electroconvulsive therapy. Arch Gen Psychiatry. Aug. 1991;48(8):746-8. [pmid: 1883258].
4 Achiffer F, Stinchfield Z, Pascual-Leone A. Prediction of clinical response to transcranial magnetic stimulation for depression by baseline lateral visual-field stimulation. Neuropsychiatry, Neuropsychology, & Behavioral Neurology. Mar. 2002. 2002;15(1):18-27.
5 Antonuccio DO, Akins WT, Chatham PM, Monagin JA, Tearnan BH, Ziegler BL. An exploratory study: the psychoeducational group treatment of drug-refractory unipolar depression. J Behav Ther Exp Psychiatry. Dec. 1984;15(4):309-13. [pmid: 6396319].
6 Aoyama Y, Hanaoka N, Kameyama M, Suda M, Sato T, Song M, et al. Stimulus intensity dependence of cerebral blood volume changes in left frontal lobe by low-frequency rTMS to right frontal lobe: A near-infrared spectroscopy study. Neurosci Res. Jan. 2009;63(1):47-51. [pmid: 18992287].
7 Aronson TA, Shukla S, Hoff A, Cook B. Proposed delusional depression subtypes: preliminary evidence from a retrospective study of phenomenology and treatment course. J Affect Disord. Jan-Feb. 1988;14(1):69-74. [pmid: 2892870].
8 Avery DH, Isenberg KE, Sampson SM, Janicak PG, Lisanby SH, Maixner DF, et al. Transcranial magnetic stimulation in the acute treatment of major depressive disorder: clinical response in an open-label extension trial. J Clin Psychiatry. Mar. 2008;69(3):441-51. [pmid: 18294022].
9 Avramov MN, Stool LA, White PF, Husain MM. Effects of nicardipine and labetalol on the acute hemodynamic response to electroconvulsive therapy. Journal of Clinical Anesthesia. 1998;10(5):394-400. [pmid: 9702620].
10 Bailine SH, Rifkin A, Kayne E, Selzer JA, Vital-Herne J, Blieka M, et al. Comparison of bifrontal and bitemporal ECT for major depression. Am J Psychiatry. Jan. 2000;157(1):121-3. [pmid: 10618025].
11 Bajbouj M, Gallinat J, Lang UE, Hellen F, Vesper J, Lisanby SH, et al. Motor cortex excitability after vagus nerve stimulation in major depression. J Clin Psychopharmacol. Apr. 2007;27(2):156-9. [pmid: 17414238].
12 Barbee JG, Jamhour NJ. Lamotrigine as an augmentation agent in treatment-resistant depression. Journal of Clinical Psychiatry. 2002;63(8):737-41. [pmid: 12197456].
13 Bauer M, Pfennig A, Linden M, Smolka MN, Neu P, Adli M. Efficacy of an algorithm-guided treatment compared with treatment as usual: a randomized, controlled study of inpatients with depression. J Clin Psychopharmacol. Aug. 2009;29(4):327-33. [pmid: 19593170].
14 Beale MD, Kellner CH, Pritchett JT, Bernstein HJ, Burns CM, Knapp R. Stimulus dose-titration in ECT: A 2-year clinical experience. Convulsive Therapy. 1994;10(2):171-6. [pmid: 8069643].
15 Bean GJ, Marchese V, Martin BA. Electric stimulus energy and the clinical response to electroconvulsive therapy. Can J Psychiatry. Nov. 1991;36(9):637-44. [pmid: 1773399].
16 Beasley CM Jr, Sayler ME, Cunningham GE, Weiss AM, Masica DN. Fluoxetine in tricyclic refractory major depressive disorder. J Affect Disord. Nov. 1990;20(3):193-200. [pmid: 2148340].
17 Bergsholm P, Larsen JL, Rosendahl K, Holsten F. Electroconvulsive therapy and cerebral computed tomography. A prospective study. Acta Psychiatr Scand. Dec. 1989;80(6):566-72. [pmid: 2618780].
18 Beutler LE, Engle D, Mohr D, Daldrup RJ, Bergan J, Meredith K, et al. Predictors of differential response to cognitive, experiential, and self-directed psychotherapeutic procedures. J Consult Clin Psychol. Apr. 1991;59(2):333-40. [pmid: 2030196].
19 Birkenhager TK, Renes JW, Pluijms EM. One-year follow-up after successful ECT: a naturalistic study in depressed inpatients. J Clin Psychiatry. Jan. 2004;65(1):87-91. [pmid: 14744175].
20 Birkenhager TK, van den Broek WW, Moleman P, Bruijn JA. Outcome of a 4-step treatment algorithm for depressed inpatients. J Clin Psychiatry. Aug. 2006;67(8):1266-71. [pmid: 16965206].
21 Birkenhager TK, Van Den Broek WW, Mulder PGH, De Lely A. One-year outcome of psychotic depression after successful electroconvulsive therapy. J ECT. 2005;21(4):221-6. [pmid: 16301881].
22 Birkenhäger TK, van den Broek WW, Wijkstra J, Bruijn JA, van Os E, Boks M, et al. Treatment of unipolar psychotic depression: An open study of lithium addition in refractory psychotic depression. Journal of Clinical Psychopharmacology. 2009;29(5):513-5. [pmid: 19745662].
23 Bosboom PR, Deijen JB. Age-related cognitive effects of ECT and ECT-induced mood improvement in depressive patients. Depress Anxiety. 2006;23(2):93-101. [pmid: 16400627].
24 Bowman ES, Coons PM. The use of electroconvulsive therapy in patients with dissociative disorders. Journal of Nervous and Mental Disease. Aug. 1992;180(8):524-8. [pmid: 1500935].
25 Brodaty H, Berle D, Hickie I, Mason C. “Side effects” of ECT are mainly depressive phenomena and are independent of age. J Affect Disord. Oct. 2001;66(2-3):237-45. [pmid: 11578677].
26 Brodaty H, Hickie I, Mason C, Prenter L. A prospective follow-up study of ECT outcome in older depressed patients. J Affect Disord. Nov. 2000;60(2):101-11. [pmid: 10967369].
27 Bulbena A, Berrios GE. Cognitive function in the affective disorders: a prospective study. Psychopathology. 1993;26(1):6-12. [pmid: 8511231].
28 Butterfield NN, Graf P, Macleod BA, Ries CR, Zis AP. Propofol reduces cognitive impairment after electroconvulsive therapy. J Ect. Mar. 2004;20(1):3-9. [pmid: 15087989].
29 Calev A, Nigal D, Shapira B, Tubi N, Chazan S, Ben-Yehuda Y, et al. Early and long-term effects of electroconvulsive therapy and depression on memory and other cognitive functions. J Nerv Ment Dis. Sep. 1991;179(9):526-33. [pmid: 1919554].
30 Carty JA. An examination of the relative effectiveness of three cognitive behavioral group treatments for depression in an Australian treatment-resistant population. Dissertation Abstracts International: Section B: The Sciences and Engineering. Jul. 2001;62(1):539.
31 Casey P, Meagher D, Butler E. Personality, functioning, and recovery from major depression. J Nerv Ment Dis. Apr. 1996;184(4):240-5. [pmid: 8604034].
32 Catafau AM, Perez V, Gironell A, Martin JC, Kulisevsky J, Estorch M, et al. SPECT mapping of cerebral activity changes induced by repetitive transcranial magnetic stimulation in depressed patients: A pilot study. Psychiatry Res: Neuroimaging. May. 2001;106(3):151-60.
33 Clark CP, Alexopoulos GS, Kaplan J. Prolactin release and clinical response to electroconvulsive therapy in depressed geriatric inpatients: a preliminary report. Convuls Ther. Mar. 1995;11(1):24-31. [pmid: 7796064].
34 Cohen Y, Feldinger E, Ogorek D, Weinbroum AA. Increased propofol requirement during succeeding administrations for electroconvulsive therapy. J Clin Anesth. Jun. 2004;16(4):282-5. [pmid: 15261320].
35 Coleman EA, Sackeim HA, Prudic J, Devanand DP, McElhiney MC, Moody BJ. Subjective memory complaints prior to and following electroconvulsive therapy. Biol Psychiatry. Mar. 1. 1996;39(5):346-56. [pmid: 8704066].
36 Coppen A, Abou-Saleh MT, Milln P, Bailey J, Metcalfe M, Burns BH, et al. Lithium continuation therapy following electroconvulsive therapy. Br J Psychiatry. Oct. 1981;139:284-7. [pmid: 6799032].
37 Corcoran CD, Thomas P, Phillips J, O'Keane V. Vagus nerve stimulation in chronic treatment-resistant depression: preliminary findings of an open-label study. Br J Psychiatry. Sep. 2006;189:282-3. [pmid: 16946367].
38 Criado JM, Fernandez A, Ortiz T. Long-term effects of electroconvulsive therapy on episodic memory. Actas Esp Psiquiatr. Jan-Feb. 2007;35(1):40-6. [pmid: 17323224].
39 Cronholm B, Ottosson JO. Experimental studies of the therapeutic action of electroconvulsive therapy in endogenous depression. The role of the electrical stimulation and of the seizure studied by variation of stimulus intensity and modification by lidocaine of seizure discharge. Convuls Ther. Sep. 1996;12(3):172-94. [pmid: 8872406].
40 Curran S. Effect of paroxetine on seizure length during electroconvulsive therapy. Acta Psychiatr Scand. Sep. 1995;92(3):239-40. [pmid: 7484206].
41 Currier MB, Murray GB, Welch CC. Electroconvulsive therapy for post-stroke depressed geriatric patients. J Neuropsychiatry Clin Neurosci. Spring. 1992;4(2):140-4. [pmid: 1627974].
42 Daly JJ, Prudic J, Devanand DP, Nobler MS, Lisanby SH, Peyser S, et al. ECT in bipolar and unipolar depression: Differences in speed of response. Bipolar Disorders. 2001;3(2):95-104. [pmid: 11333069].
43 Dannon PN, Grunhaus L. Effect of electroconvulsive therapy in repetitive transcranial magnetic stimulation nonresponder MDD patients: A preliminary study. International Journal of Neuropsychopharmacology. Sep. 2001;4(3):265-8. [pmid: 11602032].
44 Dell'Osso B, Mundo E, D'Urso N, Pozzoli S, Buoli M, Ciabatti MT, et al. Augmentative repetitive navigated transcranial magnetic stimulation (rTMS) in drug-resistant bipolar depression. Bipolar Disorders. Feb. 2009;11(1):76-81. [pmid: 19133969].
45 Delva NJ, Brunet DG, Hawken ER, Kesteven RM, Lawson JS, Lywood DW, et al. Characteristics of responders and nonresponders to brief-pulse right unilateral ECT in a controlled clinical trial. J Ect. Jun. 2001;17(2):118-23. [pmid: 11417922].
46 Devanand DP, Fitzsimons L, Prudic J, Sackeim HA. Subjective side effects during electroconvulsive therapy. Convuls Ther. Dec. 1995;11(4):232-40. [pmid: 8919573].
47 Dombrovski AY, Mulsant BH, Haskett RF, Prudic J, Begley AE, Sackeim HA. Predictors of remission after electroconvulsive therapy in unipolar major depression. J Clin Psychiatry. Aug. 2005;66(8):1043-9. [pmid: 16086621].
48 Dubovsky SL, Buzan R, Thomas M, Kassner C, Cullum CM. Nicardipine improves the antidepressant action of ECT but does not improve cognition. J Ect. Mar. 2001;17(1):3-10. [pmid: 11281512].
49 Engelhardt W, Carl G, Hartung E. Intraindividual open comparison of burst-suppression-isoflurane-anaesthesia versus electroconvulsive therapy in the treatment of severe depression. Eur J Anaesthesiol. Mar. 1993;10(2):113-8. [pmid: 8462536].
50 Epstein CM, Evatt ML, Funk A, Girard-Siqueira L, Lupei N, Slaughter L, et al. An open study of repetitive transcranial magnetic stimulation in treatment-resistant depression with Parkinson's disease. Clin Neurophysiol. Oct. 2007;118(10):2189-94. [pmid: 17714987].
51 Epstein CM, Figiel GS, McDonald WM, Amazon-Leece J, Figiel L. Rapid rate transcranial magnetic stimulation in young and middle-aged refractory depressed patients. Psychiatric Annals. Jan. 1998;28(1):36-9.
52 Eschweiler GW, Plewnia C, Batra A, Bartels M. Does clinical response to repetitive prefrontal transcranial magnetic stimulation (rTMS) predict response to electroconvulsive therapy (ECT) in cases of major depression?. The Canadian Journal of Psychiatry. La Revue canadienne de psychiatrie. Nov. 2000. 2000;45(9):845-6.
53 Eschweiler GW, Vonthein R, Bode R, Huell M, Conca A, Peters O, et al. Clinical efficacy and cognitive side effects of bifrontal versus right unilateral electroconvulsive therapy (ECT): a short-term randomised controlled trial in pharmaco-resistant major depression. J Affect Disord. Aug. 2007;101(1-3):149-57. [pmid: 17196664].
54 Ezzat DH, Ibraheem MM, Makhawy B. The effect of Piracetam on ECT--induced memory disturbances. Br J Psychiatry. Dec. 1985;147:720-1. [pmid: 3913489].
55 Fabre I, Galinowski A, Oppenheim C, Gallarda T, Meder JF, de Montigny C, et al. Antidepressant efficacy and cognitive effects of repetitive transcranial magnetic stimulation in vascular depression: An open trial. International Journal of Geriatric Psychiatry. 2004;19(9):833-42. [pmid: 15352140].
56 Fava GA, Savron G, Grandi S, Rafanelli C. Cognitive-behavioral management of drug-resistant major depressive disorder. J Clin Psychiatry. Jun. 1997;58(6):278-82. quiz 83-4. [pmid: 9228899].
57 Fekadu A, Wooderson SC, Markopoulo K, Donaldson C, Papadopoulos A, Cleare AJ. What happens to patients with treatment-resistant depression? A systematic review of medium to long term outcome studies. J Affect Disord. Jul. 2009;116(1-2):4-11. [pmid: 19007996].
58 Fenton L, Fasula M, Ostroff R, Sanacora G. Can cognitive behavioral therapy reduce relapse rates of depression after ECT? a preliminary study. J Ect. Sep. 2006;22(3):196-8. [pmid: 16957536].
59 Figiel GS, DeLeo B, Zorumski CF, Baker K, Goewert A, Jarvis M, et al. Combined use of labetalol and nifedipine in controlling the cardiovascular response from ECT. J Geriatr Psychiatry Neurol. Jan-Mar. 1993;6(1):20-4. [pmid: 8422266].
60 Figiel GS, Epstein C, McDonald WM, Amazon-Leece J, Figiel L, Saldivia A, et al. The use of rapid-rate transcranial magnetic stimulation (rTMS) in refractory depressed patients. Journal of Neuropsychiatry & Clinical Neurosciences. Win. 1998;10(1):20-5. [pmid: 9547462].
61 Fitzgerald PB, Benitez J, de Castella AR, Brown TL, Daskalakis ZJ, Kulkarni J. Naturalistic study of the use of transcranial magnetic stimulation in the treatment of depressive relapse. Australian and New Zealand Journal of Psychiatry. Sep. 2006. 2006;40(9):764-8. [pmid: 16911751].
62 Fitzgerald PB, Hoy K, Daskalakis ZJ, Kulkarni J. A randomized trial of the antidepressant effects of low- and high-frequency transcranial magnetic stimulation in treatment-resistant depression. Depression and Anxiety. Mar. 2009. 2009;26(3):229-34. [pmid: 19105212].
63 Fitzgerald PB, Hoy K, McQueen S, Herring S, Segrave R, Been G, et al. Priming stimulation enhances the effectiveness of low-frequency right prefrontal cortex transcranial magnetic stimulation in major depression. J Clin Psychopharmacol. Feb. 2008;28(1):52-8. [pmid: 18204341].
64 Fitzgerald PB, Huntsman S, Gunewardene R, Kulkarni J, Daskalakis ZJ. A randomized trial of low-frequency right-prefrontal-cortex transcranial magnetic stimulation as augmentation in treatment-resistant major depression. Int J Neuropsychopharmacol. Dec. 2006;9(6):655-66. [pmid: 16959055].
65 Fitzgerald PB, Sritharan A, Daskalakis ZJ, de Castella AR, Kulkarni J, Egan G. A functional magnetic resonance imaging study of the effects of low frequency right prefrontal transcranial magnetic stimulation in depression. J Clin Psychopharmacol. Oct. 2007;27(5):488-92. [pmid: 17873682].
66 Flint AJ, Rifat SL. Anxious depression in elderly patients. Response to antidepressant treatment. Am J Geriatr Psychiatry. Spring. 1997;5(2):107-15. [pmid: 9106374].
67 Frank E, Grochocinski VJ, Spanier CA, Buysse DJ, Cherry CR, Houck PR, et al. Interpersonal psychotherapy and antidepressant medication: Evaluation of a sequential treatment strategy in women with recurrent major depression. Journal of Clinical Psychiatry. Jan. 2000. 2000;61(1):51-7. [pmid: 10695647].
68 Frasca TA, Iodice A, McCall WV. The relationship between changes in learning and memory after right unilateral electroconvulsive therapy. J Ect. Sep. 2003;19(3):148-50. [pmid: 12972984].
69 Fraser RM, Glass IB. Unilateral and bilateral ECT in elderly patients. A comparative study. Acta Psychiatr Scand. Jul. 1980;62(1):13-31. [pmid: 7446190].
70 Frederiksen SO, d'Elia G, Holsten F. Influence of ACTH 4-10 and unilateral ECT on primary and secondary memory in depressive patients. Eur Arch Psychiatry Neurol Sci. 1985;234(5):291-4. [pmid: 2985395].
71 Fu W, Stool LA, White PF, Husain MM. Acute hemodynamic responses to electroconvulsive therapy are not related to the duration of seizure activity. Journal of Clinical Anesthesia. 1997;9(8):653-7. [pmid: 9438894].
72 Fu W, Stool LA, White PF, Husain MM. Is oral clonidine effective in modifying the acute hemodynamic response during electroconvulsive therapy?. Anesth Analg. 1998;86(5):1127-30. [pmid: 9585310].
73 Fujita A, Nakaaki S, Segawa K, Azuma H, Sato K, Arahata K, et al. Memory, attention, and executive functions before and after sine and pulse wave electroconvulsive therapies for treatment-resistant major depression. J Ect. Jun. 2006;22(2):107-12. [pmid: 16801825].
74 Gangadhar BN, Janakiramaiah N, Subbakrishna DK, Praveen J, Reddy AK. Twice versus thrice weekly ECT in melancholia: a double-blind prospective comparison. J Affect Disord. Apr. 1993;27(4):273-8. [pmid: 8509527].
75 Geller V, Grisaru N, Abarbanel JM, Lemberg T, Belmaker RH. Slow magnetic stimulation of prefrontal cortex in depression and schizophrenia. Progress in Neuro-Psychopharmacology & Biological Psychiatry. Jan. 1997;21(1):105-10. [pmid: 9075260].
76 George MS, Wassermann EM, Williams WA, Callahan A, et al. Daily repetitive transcranial magnetic stimulation (rTMS) improves mood in depression. Neuroreport: An International Journal for the Rapid Communication of Research in Neuroscience. Oct. 1995;6(14):1853-6.
77 Gormly N, Cullen C, Watters L, Philpot M, Lawlor BA. Does psychosis predict response to ECT in depressed elderly patients?. Irish Journal of Psychological Medicine. Mar. 1999;16(1):13-5.
78 Grisaru N, Chudakov B, Yaroslavsky Y, Belmaker RH. Transcranial magnetic stimulation in mania: a controlled study. Am J Psychiatry. Nov. 1998;155(11):1608-10. [pmid: 9812128].
79 Grunhaus L, Schreiber S, Dolberg OT, Hirshman S, Dannon PN. Response to ECT in major depression: are there differences between unipolar and bipolar depression?. Bipolar Disord. 1. 2002;4:91-3. [pmid: 12479688].
80 Hamilton M. The effect of treatment on the melancholias (depressions). Br J Psychiatry. Mar. 1982;140:223-30. [pmid: 7093590].
81 Healey WV, Khan A, Noonan C. Major depression with psychosis: demographic, phenomenological, and outcome characteristics in one hospitalized population. J Nerv Ment Dis. Nov. 1990;178(11):722-3. [pmid: 1977874].
82 Heikman P, Kalska H, Katila H, Sarna S, Tuunainen A, Kuoppasalmi K. Right unilateral and bifrontal electroconvulsive therapy in the treatment of depression: a preliminary study. J Ect. Mar. 2002;18(1):26-30. [pmid: 11925518].
83 Heikman P, Katila H, Sarna S, Wahlbeck K, Kuoppasalmi K. Differential response to right unilateral ECT in depressed patients: impact of comorbidity and severity of illness [ISRCTN39974945]. BMC Psychiatry. 2002;2:2. [pmid: 11846888].
84 Heikman P, Tuunainen A, Kuoppasalmi K. Value of the initial stimulus dose in right unilateral and bifrontal electroconvulsive therapy. Psychol Med. Nov. 1999;29(6):1417-23. [pmid: 10616948].
85 Hickie I, Mason C, Parker G. Comparative validity of two measures of psychomotor function in patients with severe depression. J Affect Disord. Apr. 12. 1996;37(2-3):143-9. [pmid: 8731077].
86 Hickie I, Mason C, Parker G, Brodaty H. Prediction of ECT response: validation of a refined sign-based (CORE) system for defining melancholia. Br J Psychiatry. Jul. 1996;169(1):68-74. [pmid: 8818371].
87 Horne RL, Pettinati HM, Sugerman AA, Varga E. Comparing bilateral to unilateral electroconvulsive therapy in a randomized study with EEG monitoring. Arch Gen Psychiatry. Nov. 1985;42(11):1087-92. [pmid: 3901956].
88 Huang CC, Su TP, Wei IH. Repetitive transcranial magnetic stimulation for treating medication-resistant depression in Taiwan: a preliminary study. J Chin Med Assoc. May. 2005;68(5):210-5. [pmid: 15909725].
89 Huang CC, Wei IH, Chou YH, Su TP. Effect of age, gender, menopausal status, and ovarian hormonal level on rTMS in treatment-resistant depression. Psychoneuroendocrinology. Jul. 2008;33(6):821-31. [pmid: 18468810].
90 Husain MM, McClintock SM, Rush AJ, Knapp RG, Fink M, Rummans TA, et al. The efficacy of acute electroconvulsive therapy in atypical depression. J Clin Psychiatry. Mar. 2008;69(3):406-11. [pmid: 18278988].
91 Husain MM, Rush AJ, Fink M, Knapp R, Petrides G, Rummans T, et al. Speed of response and remission in major depressive disorder with acute electroconvulsive therapy (ECT): a Consortium for Research in ECT (CORE) report. J Clin Psychiatry. Apr. 2004;65(4):485-91. [pmid: 15119910].
92 Husain SS, Kevan IM, Linnell R, Scott AI. Electroconvulsive therapy in depressive illness that has not responded to drug treatment. J Affect Disord. Dec. 2004;83(2-3):121-6. [pmid: 15555704].
93 Huuhka M, Korpisammal L, Haataja R, Leinonen E. One-year outcome of elderly inpatients with major depressive disorder treated with ECT and antidepressants. J Ect. Sep. 2004;20(3):179-85. [pmid: 15343003].
94 Huuhka MJ, Haanpaa ML, Leinonen EV. Electroconvulsive therapy in patients with depression and fibromyalgia. Eur J Pain. Aug. 2004;8(4):371-6. [pmid: 15207518].
95 Isenberg K, Downs D, Pierce K, Svarakic D, Garcia K, Jarvis M, et al. Low Frequency rTMS Stimulation of the Right Frontal Cortex Is as Effective as High Frequency rTMS Stimulation of the Left Frontal Cortex for Antidepressant-Free, Treatment-Resistant Depressed Patients. Annals of Clinical Psychiatry. Jul-Sep. 2005;17(3):153-9. [pmid: 16433057].
96 Jagadeesh HN, Gangadhar BN, Janakiramaiah N, Subbakrishna DK, Jain S. Time dependent therapeutic effects of single electroconvulsive therapy (ECT) in endogenous depression. J Affect Disord. Apr. 1992;24(4):291-5. [pmid: 1578085].
97 Janakiramaiah N, Motreja S, Gangadhar BN, Subbakrishna DK, Parameshwara G. Once vs. three times weekly ECT in melancholia: A randomized controlled trial. Acta Psychiatrica Scandinavica. 1998;98(4):316-20. [pmid: 9821454].
98 Janicak PG, Sharma RP, Israni TH, Dowd SM, Altman E, Davis JM. Effects of unilateral-nondominant vs. bilateral ECT on memory and depression: a preliminary report. Psychopharmacol Bull. 1991;27(3):353-7. [pmid: 1775610].
99 Januel D, Dumortier G, Verdon CM, Stamatiadis L, Saba G, Cabaret W, et al. A double-blind sham controlled study of right prefrontal repetitive transcranial magnetic stimulation (rTMS): therapeutic and cognitive effect in medication free unipolar depression during 4 weeks. Prog Neuropsychopharmacol Biol Psychiatry. Jan. 2006;30(1):126-30. [pmid: 16242826].
100 Jha A, Stein G. Decreased efficacy of combined benzodiazepines and unilateral ECT in treatment of depression. Acta Psychiatr Scand. Aug. 1996;94(2):101-4. [pmid: 8883570].
101 Johanson A, Gustafson L, Risberg J, Rosen I, Sjobeck M, Silfverskiold P. Long-term follow-up in depressed patients treated with electroconvulsive therapy. J Ect. Dec. 2005;21(4):214-20. [pmid: 16301880].
102 Katona CL. Puerperal mental illness: comparisons with non-puerperal controls. Br J Psychiatry. Nov. 1982;141:447-52. [pmid: 7150880].
103 Katsikitis M, Pridmore S, Marzullo M. The facial expression measurement system in the assessment of the efficacy of transcranial magnetic stimulation in the treatment of depression. European Review of Applied Psychology. 1999;49(2):123-9.
104 Keller MB, Lavori PW, Rice J. The persistent risk of chronicity in recurrent episodes of nonbipolar major depressive disorder: A prospective follow-up. Am J Psychiatry. 1992;1431:24-8.
105 Keller MB, Shapiro RW. Major depressive disorder. Initial results from a one-year prospective naturalistic follow-up study. J Nerv Ment Dis. Dec. 1981;169(12):761-8. [pmid: 7310387].
106 Kenny MA, Williams JMG. Treatment-resistant depressed patients show a good response to Mindfulness-based Cognitive Therapy. Behaviour Research and Therapy. Mar. 2007;45(3):617-25. [pmid: 16797486].
107 Kimbrell TA, Little JT, Dunn RT, Frye MA, Greenberg BD, Wassermann EM, et al. Frequency dependence of antidepressant response to left prefrontal repetitive transcranial magnetic stimulation (rTMS) as a function of baseline cerebral glucose metabolism. Biol Psychiatry. Dec. 15. 1999;46(12):1603-13. [pmid: 10624541].
108 Kito S, Fujita K, Koga Y. Changes in regional cerebral blood flow after repetitive transcranial magnetic stimulation of the left dorsolateral prefrontal cortex in treatment-resistant depression. J Neuropsychiatry Clin Neurosci. Winter. 2008;20(1):74-80. [pmid: 18305287].
109 Klausner EJ, Clarkin JF, Spielman L, Pupo C, Abrams R, Alexopoulos GS. Late-life depression and functional disability: the role of goal-focused group psychotherapy. International Journal of Geriatric Psychiatry. 1998;13(10):707-16. [pmid: 9818307].
110 Kok RM, Nolen WA, Heeren TJ. Outcome of late-life depression after 3 years of sequential treatment. Acta Psychiatrica Scandinavica. 2009;119(4):274-81. [pmid: 19053970].
111 Kotresh S, Girish K, Janakiramaiah N, Rao GU, Gangadhar BN. Effect of ECT stimulus parameters on seizure physiology and outcome. J Ect. Mar. 2004;20(1):10-2. [pmid: 15087990].
112 Krystal AD, Holsinger T, Weiner RD, Coffey CE. Prediction of the utility of a switch from unilateral to bilateral ECT in the elderly using treatment 2 ictal EEG indices. J Ect. Dec. 2000;16(4):327-37. [pmid: 11314870].
113 Lang UE, Bajbouj M, Gallinat J, Hellweg R. Brain-derived neurotrophic factor serum concentrations in depressive patients during vagus nerve stimulation and repetitive transcranial magnetic stimulation. Psychopharmacology (Berl). Jul. 2006;187(1):56-9. [pmid: 16767416].
114 Langer G, Karazman R, Neumark J, Saletu B, Schonbeck G, Grunberger J, et al. Isoflurane narcotherapy in depressive patients refractory to conventional antidepressant drug treatment. A double-blind comparison with electroconvulsive treatment. Neuropsychobiology. 1995;31(4):182-94. [pmid: 7659199].
115 Lehmann HE, Fenton FR, Deutsch M, Feldman S, Engelsmann F. An 11-year follow-up study of 110 depressed patients. Acta Psychiatr Scand. Jul. 1988;78(1):57-65. [pmid: 3176996].
116 Lekwauwa R, McQuoid D, Steffens DC. Hippocampal volume is associated with physician-reported acute cognitive deficits after electroconvulsive therapy. J Geriatr Psychiatry Neurol. Mar. 2006;19(1):21-5. [pmid: 16449756].
117 Lerer B, Shapira B, Calev A, Tubi N, Drexler H, Kindler S, et al. Antidepressant and cognitive effects of twice- versus three-times-weekly ECT. Am J Psychiatry. Apr. 1995;152(4):564-70. [pmid: 7694905].
118 Letemendia FJ, Delva NJ, Rodenburg M, Lawson JS, Inglis J, Waldron JJ, et al. Therapeutic advantage of bifrontal electrode placement in ECT. Psychol Med. May. 1993;23(2):349-60. [pmid: 8332652].
119 Leung M, Hollander Y, Brown GR. Pretreatment with ibuprofen to prevent electroconvulsive therapy-induced headache. J Clin Psychiatry. May. 2003;64(5):551-3. [pmid: 12755658].
120 Levine J, Swartz M, Feibel H, Schreiber G. Premedication with non-selective and M1-selective muscarinic antagonists before ECT. Isr J Psychiatry Relat Sci. 1993;30(3):179-82. [pmid: 8225935].
121 Levitt AJ, Joffe RT, Kamil R, McIntyre R. Do depressed subjects who have failed both fluoxetine and a tricyclic antidepressant respond to the combination?. J Clin Psychiatry. Sep. 1999;60(9):613-6. [pmid: 10520980].
122 Li X, Nahas Z, Lomarev M, Denslow S, Shastri A, Bohning DE, et al. Prefrontal cortex transcranial magnetic stimulation does not change local diffusion: a magnetic resonance imaging study in patients with depression. Cogn Behav Neurol. Jun. 2003;16(2):128-35. [pmid: 12799599].
123 Lisanby SH, Luber B, Schlaepfer TE, Sackeim HA. Safety and feasibility of magnetic seizure therapy (MST) in major depression: randomized within-subject comparison with electroconvulsive therapy. Neuropsychopharmacology. Oct. 2003;28(10):1852-65. [pmid: 12865903].
124 Lisanby SH, Maddox JH, Prudic J, Devanand DP, Sackeim HA. The effects of electroconvulsive therapy on memory of autobiographical and public events. Arch Gen Psychiatry. Jun. 2000;57(6):581-90. [pmid: 10839336].
125 Little JT, Kimbrell TA, Wassermann EM, Grafman J, Figueras S, Dunn RT, et al. Cognitive effects of 1- and 20-hertz repetitive transcranial magnetic stimulation in depression: preliminary report. Neuropsychiatry Neuropsychol Behav Neurol. Apr. 2000;13(2):119-24. [pmid: 10780630].
126 Locala JA, Irefin SA, Malone D, Cywinski JB, Samuel SW, Naugle R. The comparative hemodynamic effects of methohexital and remifentanil in electroconvulsive therapy. J Ect. Mar. 2005;21(1):12-5. [pmid: 15791171].
127 Luborzewski A, Schubert F, Seifert F, Danker-Hopfe H, Brakemeier EL, Schlattmann P, et al. Metabolic alterations in the dorsolateral prefrontal cortex after treatment with high-frequency repetitive transcranial magnetic stimulation in patients with unipolar major depression. J Psychiatr Res. Oct. 2007;41(7):606-15. [pmid: 16600298].
128 Lykouras E, Malliaras D, Christodoulou GN, Papakostas Y, Voulgari A, Tzonou A, et al. Delusional depression: phenomenology and response to treatment. A prospective study. Acta Psychiatr Scand. Mar. 1986;73(3):324-9. [pmid: 2872774].
129 Magni G, Fisman M, Helmes E. Clinical correlates of ECT-resistant depression in the elderly. J Clin Psychiatry. Oct. 1988;49(10):405-7. [pmid: 3170492].
130 Malaspina D, Amador XF, Coleman EA, Mayr TL, Friedman JH, Sackeim HA. Smooth pursuit eye movement abnormality in severe major depression: effects of ECT and clinical recovery. J Neuropsychiatry Clin Neurosci. Winter. 1994;6(1):36-42. [pmid: 8148635].
131 Malitz S, Sackeim H, Decina P. Low dosage ECT: Electrode placement and acute physiological and cognitive effects. Am J Psychiatry. 1984;4:47-53.
132 Malitz S, Sackeim HA, Decina P, Kanzler M, Kerr B. The efficacy of electroconvulsive therapy. Dose-response interactions with modality. Ann N Y Acad Sci. 1986;462:56-64. [pmid: 3458419].
133 Marangell LB, Rush AJ, George MS, Sackeim HA, Johnson CR, Husain MM, et al. Vagus nerve stimulation (VNS) for major depressive episodes: one year outcomes. Biol Psychiatry. Feb. 15. 2002;51(4):280-7. [pmid: 11958778].
134 Martis B, Alam D, Dowd SM, Hill SK, Sharma RP, Rosen C, et al. Neurocognitive effects of repetitive transcranial magnetic stimulation in severe major depression. Clin Neurophysiol. Jun. 2003;114(6):1125-32. [pmid: 12804681].
135 Mayberg HS, Lozano AM, Voon V, McNeely HE, Seminowicz D, Hamani C, et al. Deep brain stimulation for treatment-resistant depression. Neuron. Mar. 3. 2005;45(5):651-60. [pmid: 15748841].
136 Mayur PM, Shree RS, Gangadhar BN, Subbakrishna DK, Janakiramaiah N, Rao GSU. Atropine premedication and the cardiovascular response to electroconvulsive therapy. British Journal of Anaesthesia. 1998;81(3):466-7. [pmid: 9861141].
137 McCall WV, Colenda CC, Farah BA. Ictal EEG regularity declines during a course of RUL ECT. Convuls Ther. Dec. 1996;12(4):213-6. [pmid: 9034695].
138 McCall WV, Dunn A, Rosenquist PB. Quality of life and function after electroconvulsive therapy. Br J Psychiatry. Nov. 2004;185:405-9. [pmid: 15516549].
139 McCall WV, Dunn A, Rosenquist PB, Hughes D. Markedly suprathreshold right unilateral ECT versus minimally suprathreshold bilateral ECT: antidepressant and memory effects. J Ect. Sep. 2002;18(3):126-9. [pmid: 12394530].
140 McCall WV, Farah BA, Reboussin D, Colenda CC. Comparison of the efficacy of titrated, moderate-dose and fixed, high- dose right unilateral ECT in elderly patients. American Journal of Geriatric Psychiatry. 1995;3(4):317-24.
141 McCall WV, Reboussin BA, Cohen W, Lawton P. Electroconvulsive therapy is associated with superior symptomatic and functional change in depressed patients after psychiatric hospitalization. J Affect Disord. Mar. 2001;63(1-3):17-25. [pmid: 11246076].
142 McCall WV, Reboussin DM, Weiner RD, Sackeim HA. Titrated moderately suprathreshold vs fixed high-dose right unilateral electroconvulsive therapy: acute antidepressant and cognitive effects. Arch Gen Psychiatry. May. 2000;57(5):438-44. [pmid: 10807483].
143 McDonald WM, Easley K, Byrd EH, Holtzheimer P, Tuohy S, Woodard JL, et al. Combination rapid transcranial magnetic stimulation in treatment refractory depression. Neuropsychiatric Disease and Treatment. Jan. 2006;2(1):85-94. [pmid: 19412449].
144 McPherson S, Cairns P, Carlyle J, Shapiro DA, Richardson P, Taylor D. The effectiveness of psychological treatments for treatment-resistant depression: a systematic review. Acta Psychiatr Scand. May. 2005;111(5):331-40. [pmid: 15819726].
145 Meyers BS, Klimstra SA, Gabriele M, Hamilton M, Kakuma T, Tirumalasetti F, et al. Continuation treatment of delusional depression in older adults. Am J Geriatr Psychiatry. Fall. 2001;9(4):415-22. [pmid: 11739068].
146 Meyers BS, Mei-Tal V. Empirical study on an inpatient psychogeriatric unit: biological treatment in patients with depressive illness. Int J Psychiatry Med. 1985;15(2):111-24. [pmid: 2865228].
147 Miller IW, Bishop SB, Norman WH, Keitner GI. Cognitive/behavioural therapy and pharmacotherapy with chronic, drug-refractory depressed inpatients: A note of optimism. Behavioural Psychotherapy. Oct. 1985;13(4):320-7.
148 Miniussi C, Bonato C, Bignotti S, Gazzoli A, Gennarelli M, Pasqualetti P, et al. Repetitive transcranial magnetic stimulation (rTMS) at high and low frequency: an efficacious therapy for major drug-resistant depression?. Clin Neurophysiol. May. 2005;116(5):1062-71. [pmid: 15826846].
149 Mu Q, Bohning DE, Nahas Z, Walker J, Anderson B, Johnson KA, et al. Acute vagus nerve stimulation using different pulse widths produces varying brain effects. Biol Psychiatry. Apr. 15. 2004;55(8):816-25. [pmid: 15050863].
150 Mueller TI, Leon AC, Keller MB, Solomon DA, Endicott J, Coryell W, et al. Recurrence after recovery from major depressive disorder during 15 years of observational follow-up. Am J Psychiatry. Jul. 1999;156(7):1000-6. [pmid: 10401442].
151 Mulsant BH, Rosen J, Thornton JE, Zubenko GS. A prospective naturalistic study of electroconvulsive therapy in late-life depression. J Geriatr Psychiatry Neurol. Jan-Mar. 1991;4(1):3-13. [pmid: 2054049].
152 Nahas Z, Kunik ME, Orengo CA, Molinari V, Workman R. Depression in male geropsychiatric inpatients with and without dementia: a naturalistic study. J Affect Disord. Dec. 1997;46(3):243-6. [pmid: 9547120].
153 Nahas Z, Li X, Kozel FA, Mirzki D, Memon M, Miller K, et al. Safety and benefits of distance-adjusted prefrontal transcranial magnetic stimulation in depressed patients 55-75 years of age: a pilot study. Depress Anxiety. 2004;19(4):249-56. [pmid: 15274174].
154 Nahas Z, Marangell LB, Husain MM, Rush AJ, Sackeim HA, Lisanby SH, et al. Two-year outcome of vagus nerve stimulation (VNS) for treatment of major depressive episodes. J Clin Psychiatry. Sep. 2005;66(9):1097-104. [pmid: 16187765].
155 Nakajima S, Ishida T, Akaishi R, Takahata K, Kitahata R, Uchida H, et al. Impacts of switching antidepressants after successful electroconvulsive therapy on the maintenance of clinical remission in patients with treatment-resistant depression: A chart review. The Journal of ECT. 2009;25(3):178-81. [pmid: 19710625].
156 Navarro V, Gasto C, Lomena F, Mateos JJ, Portella MJ, Massana G, et al. Frontal cerebral perfusion after antidepressant drug treatment versus ECT in elderly patients with major depression: a 12-month follow-up control study. J Clin Psychiatry. May. 2004;65(5):656-61. [pmid: 15163251].
157 Neu P, Heuser I, Bajbouj M. Cerebral blood flow during vagus nerve stimulation--a transcranial Doppler study. Neuropsychobiology. 2005;51(4):265-8. [pmid: 15905632].
158 Ng RMK. Cognitive Therapy for Obsessive-compulsive Personality Disorder - A Pilot Study in Hong Kong Chinese Patients. Hong Kong J Psychiatry. Jun. 2005;15(2):50-3.
159 Nguyen TT, Chhibber AK, Lustik SJ, Kolano JW, Dillon PJ, Guttmacher LB. Effect of methohexitone and propofol with or without alfentanil on seizure duration and recovery in electroconvulsive therapy. British Journal of Anaesthesia. 1997;79(6):801-3. [pmid: 9496217].
160 Nobler MS, Oquendo MA, Kegeles LS, Malone KM, Campbell CC, Sackeim HA, et al. Decreased regional brain metabolism after ect. Am J Psychiatry. Feb. 2001;158(2):305-8. [pmid: 11156816].
161 Nolen WA, van de Putte JJ, Dijken WA, Kamp JS, Blansjaar BA, Kramer HJ, et al. Treatment strategy in depression. II. MAO inhibitors in depression resistant to cyclic antidepressants: two controlled crossover studies with tranylcypromine versus L-5-hydroxytryptophan and nomifensine. Acta Psychiatr Scand. Dec. 1988;78(6):676-83. [pmid: 3146891].
162 O'Connor MK, Knapp R, Husain M, Rummans TA, Petrides G, Smith G, et al. The influence of age on the response of major depression to electroconvulsive therapy: a C.O.R.E. Report. Am J Geriatr Psychiatry. Fall. 2001;9(4):382-90. [pmid: 11739064].
163 O'Keane V, Dinan TG, Scott L, Corcoran C. Changes in hypothalamic-pituitary-adrenal axis measures after vagus nerve stimulation therapy in chronic depression. Biol Psychiatry. Dec. 15. 2005;58(12):963-8. [pmid: 16005439].
164 O'Leary D, Gill D, Gregory S, Shawcross C. Which depressed patients respond to ECT? The Nottingham results. Journal of Affective Disorders. 1995;33(4):245-50. [pmid: 7790678].
165 O'Leary DA, Lee AS. Seven year prognosis in depression. Mortality and readmission risk in the Nottingham ECT cohort. Br J Psychiatry. Oct. 1996;169(4):423-9. [pmid: 8894191].
166 Pagnin D, de Queiroz V, Pini S, Cassano GB. Efficacy of ECT in depression: a meta-analytic review. J Ect. Mar. 2004;20(1):13-20. [pmid: 15087991].
167 Parker G, Hadzi-Pavlovic D, Hickie I, Mitchell P, Wilhelm K, Brodaty H, et al. Psychotic depression: a review and clinical experience. Aust N Z J Psychiatry. Jun. 1991;25(2):169-80. [pmid: 1678937].
168 Peretti CS, Danion JM, Grange D, Mobarek N. Bilateral ECT and autobiographical memory of subjective experiences related to melancholia: a pilot study. J Affect Disord. Nov. 4. 1996;41(1):9-15. [pmid: 8938200].
169 Petrides G, Fink M, Husain MM, Knapp RG, Rush AJ, Mueller M, et al. ECT remission rates in psychotic versus nonpsychotic depressed patients: a report from CORE. J Ect. Dec. 2001;17(4):244-53. [pmid: 11731725].
170 Pettinati HM, Rosenberg J. Memory self-ratings before and after electroconvulsive therapy: depression-versus ECT induced. Biol Psychiatry. Apr. 1984;19(4):539-48. [pmid: 6733173].
171 Pisvejc J, Hyrman V, Sikora J, Berankova A, Kobeda B, Auerova M, et al. A comparison of brief and ultrabrief pulse stimuli in unilateral ECT. J Ect. Jun. 1998;14(2):68-75. [pmid: 9641801].
172 Prakash J, Kotwal A, Prabhu HRA. Therapeutic and Prophylactic Utility of the Memory-Enhancing Drug Donepezil Hydrochloride on Cognition of Patients Undergoing Electroconvulsive Therapy: A Randomized Controlled Trial. Journal of ECT. Sep. 2006;22(3):163-8. [pmid: 16957530].
173 Pridmore S, Rybak M, Turnier-Shea Y, Reid P, Bruno PR, Couper D. A naturalistic study of response in melancholia to transcranial magnetic stimulation (TMS). German Journal of Psychiatry. 1999;2(1):13-21.
174 Prohovnik I, Sackeim HA, Decina P, Malitz S. Acute reductions of regional cerebral blood flow following electroconvulsive therapy. Interactions with modality and time. Ann N Y Acad Sci. 1986;462:249-62. [pmid: 3458407].
175 Prudic J, Haskett RF, Mulsant B, Malone KM, Pettinati HM, Stephens S, et al. Resistance to antidepressant medications and short-term clinical response to ECT. Am J Psychiatry. Aug. 1996;153(8):985-92. [pmid: 8678194].
176 Prudic J, Olfson M, Marcus SC, Fuller RB, Sackeim HA. Effectiveness of electroconvulsive therapy in community settings. Biol Psychiatry. Feb. 1. 2004;55(3):301-12. [pmid: 14744473].
177 Prudic J, Sackeim HA, Decina P, Hopkins N, Ross FR, Malitz S. Acute effects of ECT on cardiovascular functioning: relations to patient and treatment variables. Acta Psychiatr Scand. Apr. 1987;75(4):344-51. [pmid: 3591419].
178 Prudic J, Sackeim HA, Devanand DP, Krueger RB, Settembrino JM. Acute cognitive effects of subconvulsive electrical stimulation. Convuls Ther. Mar. 1994;10(1):4-24. [pmid: 8055291].
179 Raes F, Sienaert P, Demyttenaere K, Peuskens J, Williams JMG, Hermans D. Overgeneral memory predicts stability of short-term outcome of electroconvulsive therapy for depression. Journal of ECT. 2008;24(1):81-3. [pmid: 18379339].
180 Ranjkesh F, Barekatain M, Akuchakian S. Bifrontal versus right unilateral and bitemporal electroconvulsive therapy in major depressive disorder. J Ect. Dec. 2005;21(4):207-10. [pmid: 16301878].
181 Rasmussen KG, Black JL. Serotonin transporter gene status and electroconvulsive therapy outcomes: a retrospective analysis of 83 patients. J Clin Psychiatry. Jan. 2009;70(1):92-4. [pmid: 19192461].
182 Rasmussen KG, Mueller M, Knapp RG, Husain MM, Rummans TA, Sampson SM, et al. Antidepressant medication treatment failure does not predict lower remission with ECT for major depressive disorder: A report from the consortium for research in electroconvulsive therapy. J Clin Psychiatry. 2007;68(11):1701-6. [pmid: 18052563].
183 Rasmussen KG, Snyder KA, Knapp RG, Mueller M, Yim E, Husain MM, et al. Relationship between somatization and remission with ECT. Psychiatry Res. Dec. 30. 2004;129(3):293-5. [pmid: 15661324].
184 Reynaert-Dupuis C, Zdanowicz N, Group AG-BS, Leyman S, Mignon A, Seghers S. Efficacy and tolerance of venlafaxine in depressed patients switched from prior antidepressant treatment. PRIMARY CARE PSYCHIATRY. 2002;8:63-8.
185 Rich CL, Spiker DG, Jewell SW. The efficiency of ECT: I. Response rate in depressive episodes. Psychiatry Research. 1984;11(3):167-76. [pmid: 6587410].
186 Rich CL, Spiker DG, Jewell SW, Neil JF, Phillipson M. ECT response in psychotic versus nonpsychotic unipolar depressives. J Clin Psychiatry. Mar. 1986;47(3):123-5. [pmid: 3949720].
187 Riddle WJ, Scott AI, Bennie J, Carroll S, Fink G. Current intensity and oxytocin release after electroconvulsive therapy. Biol Psychiatry. Jun. 1-15. 1993;33(11-12):839-41. [pmid: 8373922].
188 Robin A, De Tissera S. A double-blind controlled comparison of the therapeutic effects of low and high energy electroconvulsive therapies. Br J Psychiatry. Oct. 1982;141:357-66. [pmid: 6756529].
189 Rodger CR, Scott AI, Whalley LJ. Is there a delay in the onset of the antidepressant effect of electroconvulsive therapy?. Br J Psychiatry. Jan. 1994;164(1):106-9. [pmid: 8137089].
190 Roemer RA, Shagass C, Dubin W, Jaffe R, Katz R. Relationship between pretreatment electroencephalographic coherence measures and subsequent response to electroconvulsive therapy: a preliminary study. Neuropsychobiology. 1990;24(3):121-4. [pmid: 2135066].
191 Rosenberg PB, Mehndiratta RB, Mehndiratta YP, Wamer A, Rosse RB, Balish M. Repetitive transcranial magnetic stimulation treatment of comorbid posttraumatic stress disorder and major depression. J Neuropsychiatry Clin Neurosci. Summer. 2002;14(3):270-6. [pmid: 12154150].
192 Rossini D, Magri L, Lucca A, Giordani S, Smeraldi E, Zanardi R. Does rTMS hasten the response to escitalopram, sertraline, or venlafaxine in patients with major depressive disorder? A double-blind, randomized, sham-controlled trial. J Clin Psychiatry. Dec. 2005;66(12):1569-75. [pmid: 16401159].
193 Rush AJ, Sackeim HA, Marangell LB, George MS, Brannan SK, Davis SM, et al. Effects of 12 months of vagus nerve stimulation in treatment-resistant depression: a naturalistic study. Biol Psychiatry. Sep. 1. 2005;58(5):355-63. [pmid: 16139581].
194 Russell JC, Rasmussen KG, O'Connor MK, Copeman CA, Ryan DA, Rummans TA. Long-term maintenance ECT: A retrospective review of efficacy and cognitive outcome. Journal of ECT. 2003;19(1):4-9. [pmid: 12621270].
195 Rybak M, Bruno R, Turnier-Shea Y, Pridmore S. An attempt to increase the rate and magnitude of the antidepressant effect of transcranial magnetic stimulation (TMS) a pilot study. German Journal of Psychiatry. 2005;8(4):59-65.
196 Sackeim H, Decina P, Prohovnik I, Malitz S. Seizure threshold in electroconvulsive therapy. Effects of sex, age, electrode placement, and number of treatments. Arch Gen Psychiatry. Apr. 1987;44(4):355-60. [pmid: 3566457].
197 Sackeim HA, Brannan SK, Rush AJ, George MS, Marangell LB, Allen J. Durability of antidepressant response to vagus nerve stimulation (VNS). Int J Neuropsychopharmacol. Dec. 2007;10(6):817-26. [pmid: 17288644].
198 Sackeim HA, Decina P, Portnoy S, Neeley P, Malitz S. Studies of dosage, seizure threshold, and seizure duration in ECT. Biol Psychiatry. Mar. 1987;22(3):249-68. [pmid: 3814678].
199 Sackeim HA, Dillingham EM, Prudic J, Cooper T, McCall WV, Rosenquist P, et al. Effect of concomitant pharmacotherapy on electroconvulsive therapy outcomes: short-term efficacy and adverse effects. Arch Gen Psychiatry. Jul. 2009;66(7):729-37. [pmid: 19581564].
200 Sackeim HA, Freeman J, McElhiney M, Coleman E, Prudic J, Devanand DP. Effects of major depression on estimates of intelligence. J Clin Exp Neuropsychol. Mar. 1992;14(2):268-88. [pmid: 1572949].
201 Sackeim HA, Keilp JG, Rush AJ, George MS, Marangell LB, Dormer JS, et al. The effects of vagus nerve stimulation on cognitive performance in patients with treatment-resistant depression. Neuropsychiatry Neuropsychol Behav Neurol. Jan. 2001;14(1):53-62. [pmid: 11234909].
202 Sackeim HA, Luber B, Moeller JR, Prudic J, Devanand DP, Nobler MS. Electrophysiological correlates of the adverse cognitive effects of electroconvulsive therapy. J Ect. Jun. 2000;16(2):110-20. [pmid: 10868321].
203 Sackeim HA, Portnoy S, Neeley P. Cognitive consequences of low-dosage electroconvulsive therapy. Annals of the New York Academy of Sciences. 1986;462:326-40. [pmid: 3458413].
204 Sackeim HA, Prudic J, Devanand DP, Decina P, Kerr B, Malitz S. The impact of medication resistance and continuation pharmacotherapy on relapse following response to electroconvulsive therapy in major depression. J Clin Psychopharmacol. Apr. 1990;10(2):96-104. [pmid: 2341598].
205 Sackeim HA, Prudic J, Devanand DP, Kiersky JE, Fitzsimons L, Moody BJ, et al. Effects of stimulus intensity and electrode placement on the efficacy and cognitive effects of electroconvulsive therapy. N Engl J Med. Mar. 25. 1993;328(12):839-46. [pmid: 8441428].
206 Sackeim HA, Prudic J, Devanand DP, Nobler MS, Lisanby SH, Peyser S, et al. A prospective, randomized, double-blind comparison of bilateral and right unilateral electroconvulsive therapy at different stimulus intensities. Arch Gen Psychiatry. 2000;57(5):425-34. [pmid: 10807482].
207 Sackeim HA, Prudic J, Fuller R, Keilp J, Lavori PW, Olfson M. The cognitive effects of electroconvulsive therapy in community settings. Neuropsychopharmacology. Jan. 2007;32(1):244-54. [pmid: 16936712].
208 Sackeim HA, Prudic J, Nobler MS, Fitzsimons L, Lisanby SH, Payne N, et al. Effects of pulse width and electrode placement on the efficacy and cognitive effects of electroconvulsive therapy. Brain Stimulation. 2008;1(2):71-83. [pmid: 19756236].
209 Sackeim HA, Rush AJ, George MS, Marangell LB, Husain MM, Nahas Z, et al. Vagus nerve stimulation (VNS) for treatment-resistant depression: efficacy, side effects, and predictors of outcome. Neuropsychopharmacology. Nov. 2001;25(5):713-28. [pmid: 11682255].
210 Sanacora G, Fenton LR, Fasula MK, Rothman DL, Levin Y, Krystal JH, et al. Cortical gamma-aminobutyric acid concentrations in depressed patients receiving cognitive behavioral therapy. Biol Psychiatry. Feb. 1. 2006;59(3):284-6. [pmid: 16139814].
211 Schlaepfer TE, Frick C, Zobel A, Maier W, Heuser I, Bajbouj M, et al. Vagus nerve stimulation for depression: efficacy and safety in a European study. Psychol Med. May. 2008;38(5):651-61. [pmid: 18177525].
212 Schule C, Zwanzger P, Baghai T, Mikhaiel P, Thoma H, Moller HJ, et al. Effects of antidepressant pharmacotherapy after repetitive transcranial magnetic stimulation in major depression: an open follow-up study. J Psychiatr Res. Mar-Apr. 2003;37(2):145-53. [pmid: 12842168].
213 Scocco P, Frank E. Interpersonal psychotherapy as augmentation treatment in depressed elderly responding poorly to antidepressant drugs: A case series. Psychotherapy and Psychosomatics. Nov-Dec. 2002;71(6):357-61. [pmid: 12411771].
214 Scott AI, Rodger CR, Stocks RH, Shering AP. Is old-fashioned electroconvulsive therapy more efficacious? A randomised comparative study of bilateral brief-pulse and bilateral sine-wave treatments. Br J Psychiatry. Mar. 1992;160:360-4. [pmid: 1562862].
215 Scott J, Eccleston D, Boys R. Can we predict the persistence of depression?. Br J Psychiatry. Nov. 1992;161:633-7. [pmid: 1422613].
216 Segman RH, Shapira B, Gorfine M, Lerer B. Onset and time course of antidepressant action: psychopharmacological implications of a controlled trial of electroconvulsive therapy. Psychopharmacology (Berl). Jun. 1995;119(4):440-8. [pmid: 7480524].
217 Serra M, Gasto C, Navarro V, Torres X, Blanch J, Masana G. Maintenance electroconvulsive therapy in elderly psychotic unipolar depression. Medicina Clinica. 2006;126(13):491-2. [pmid: 16624227].
218 Shapira B, Lerer B. Speed of response to bilateral ECT: an examination of possible predictors in two controlled trials. J Ect. Sep. 1999;15(3):202-6. [pmid: 10492858].
219 Shapira B, Lerer B, Kindler S, Lichtenberg P, Gropp C, Cooper T, et al. Enhanced serotonergic responsivity following electroconvulsive therapy in patients with major depression. Br J Psychiatry. Feb. 1992;160:223-9. [pmid: 1540763].
220 Shapira B, Tubi N, Drexler H, Lidsky D, Calev A, Lerer B. Cost and benefit in the choice of ECT schedule. Twice versus three times weekly ECT. Br J Psychiatry. Jan. 1998;172:44-8. [pmid: 9534831].
221 Shapira B, Tubi N, Lerer B. Balancing speed of response to ECT in major depression and adverse cognitive effects: role of treatment schedule. J Ect. Jun. 2000;16(2):97-109. [pmid: 10868320].
222 Sharpley AL, Bhagwagar Z, Hafizi S, Whale WR, Gijsman HJ, Cowen PJ. Risperidone augmentation decreases rapid eye movement sleep and decreases wake in treatment-resistant depressed patients. J Clin Psychiatry. Feb. 2003;64(2):192-6. [pmid: 12633128].
223 Sienaert P, Vansteelandt K, Demyttenaere K, Peuskens J. Ultra-brief pulse ECT in bipolar and unipolar depressive disorder: Differences in speed of response. Bipolar Disorders. 2009;11(4):418-24. [pmid: 19500095].
224 Sobin C, Prudic J, Devanand DP, Nobler MS, Sackeim HA. Who responds to electroconvulsive therapy? A comparison of effective and ineffective forms of treatment. Br J Psychiatry. Sep. 1996;169(3):322-8. [pmid: 8879718].
225 Sobin C, Sackeim HA, Prudic J, Devanand DP, Moody BJ, McElhiney MC. Predictors of retrograde amnesia following ECT. Am J Psychiatry. Jul. 1995;152(7):995-1001. [pmid: 7793470].
226 Sood N, Treglia M, Obenchain RL, Dulisse B, Melfi CA, Croghan TW. Determinants of antidepressant treatment outcome. Am J Manag Care. 2000;6(12):1327-36. [pmid: 11151810].
227 Speer AM, Kimbrell TA, Wasermann EM, Repella JD, Willis MW, Herscovitch P, et al. Opposite effects of high and low frequency rTMS on regional brain activity in depressed patients. Biological Psychiatry. Dec. 2000;48(12):1133-41. [pmid: 11137053].
228 Spronk D, Arns M, Bootsma A, van Ruth R, Fitzgerald PB. Long-term effects of left frontal rTMS on EEG and ERPs in patients with depression. Clin EEG Neurosci. Jul. 2008;39(3):118-24. [pmid: 18751560].
229 Steffens DC, McQuoid DR, Krishnan KR. The Duke Somatic Treatment Algorithm for Geriatric Depression (STAGED) approach. Psychopharmacol Bull. Spring. 2002;36(2):58-68. [pmid: 12397841].
230 Stek ML, van der Wurff FB, Uitdehaag BMJ, Beekman ATF, Hoogendijk WJG. ECT in the treatment of depressed elderly: lessons from a terminated clinical trial. International Journal of Geriatric Psychiatry. 2007;22(10):1052-4. [pmid: 17457952].
231 Stimpson N, Agrawal N, Lewis G. Randomised controlled trials investigating pharmacological and psychological interventions for treatment-refractory depression. British Journal of Psychiatry. 2002;181:284-94. [pmid: 12356654].
232 Stoppe A, Louza M, Rosa M, Gil G, Rigonatti S. Fixed high-dose electroconvulsive therapy in the elderly with depression: a double-blind, randomized comparison of efficacy and tolerability between unilateral and bilateral electrode placement. J Ect. Jun. 2006;22(2):92-9. [pmid: 16801822].
233 Stoudemire A, Hill CD, Dalton ST, Marquardt MG. Rehospitalization rates in older depressed adults after antidepressant and electroconvulsive therapy treatment. J Am Geriatr Soc. Dec. 1994;42(12):1282-5. [pmid: 7983293].
234 Stoudemire A, Hill CD, Marquardt M, Dalton S, Lewison BJ. Recovery and relapse in geriatric depression after treatment with antidepressants and ECT in a medical-psychiatric population. Gen Hosp Psychiatry. May. 1998;20(3):170-4. [pmid: 9650035].
235 Stoudemire A, Hill CD, Morris R, Lewison BJ. Long-term outcome of treatment-resistant depression in older adults. Am J Psychiatry. Oct. 1993;150(10):1539-40. [pmid: 8379561].
236 Stoudemire A, Hill CD, Morris R, Martino-Saltzman D, Markwalter H, Lewison B. Cognitive outcome following tricyclic and electroconvulsive treatment of major depression in the elderly. Am J Psychiatry. Oct. 1991;148(10):1336-40. [pmid: 1897613].
237 Stoudemire A, Knos G, Gladson M, Markwalter H, Sung YF, Morris R, et al. Labetalol in the control of cardiovascular responses to electroconvulsive therapy in high-risk depressed medical patients. J Clin Psychiatry. Dec. 1990;51(12):508-12. [pmid: 2258364].
238 Surtees PG, Barkley C. Future imperfect: the long-term outcome of depression. Br J Psychiatry. Mar. 1994;164(3):327-41. [pmid: 8199786].
239 Talbot NL, Conwell Y, O'Hara MW, Stuart S, Ward EA, Gamble SA, et al. Interpersonal psychotherapy for depressed women with sexual abuse histories: a pilot study in a community mental health center. J Nerv Ment Dis. Dec. 2005;193(12):847-50. [pmid: 16319710].
240 Taylor MA, Abrams R. Short-term cognitive effects of unilateral and bilateral ECT. British Journal of Psychiatry. 1985;146(MAR.):308-11. [pmid: 3986441].
241 Tew JD Jr, Mulsant BH, Haskett RF, Dolata D, Hixson L, Mann JJ. A randomized comparison of high-charge right unilateral electroconvulsive therapy and bilateral electroconvulsive therapy in older depressed patients who failed to respond to 5 to 8 moderate-charge right unilateral treatments. J Clin Psychiatry. Dec. 2002;63(12):1102-5. [pmid: 12523868].
242 Tew JD Jr, Mulsant BH, Haskett RF, Joan P, Begley AE, Sackeim HA. Relapse during continuation pharmacotherapy after acute response to ECT: a comparison of usual care versus protocolized treatment. Ann Clin Psychiatry. Jan-Mar. 2007;19(1):1-4. [pmid: 17453654].
243 Tew JD Jr, Mulsant BH, Haskett RF, Prudic J, Thase ME, Crowe RR, et al. Acute efficacy of ECT in the treatment of major depression in the old-old. Am J Psychiatry. Dec. 1999;156(12):1865-70. [pmid: 10588398].
244 Thase ME, Frank E, Mallinger AG, Hamer T, Kupfer DJ. Treatment of imipramine-resistant recurrent depression, III: Efficacy of monoamine oxidase inhibitors. J Clin Psychiatry. Jan. 1992;53(1):5-11. [pmid: 1737741].
245 Thase ME, Kupfer DJ, Frank E, Jarrett DB. Treatment of imipramine-resistant recurrent depression: II. An open clinical trial of lithium augmentation. J Clin Psychiatry. Nov. 1989;50(11):413-7. [pmid: 2509437].
246 Thase ME, Reynolds CF, Frank E, Simons AD, et al. Response to cognitive-behavioral therapy in chronic depression. Journal of Psychotherapy Practice & Research. Sum. 1994;3(3):204-14.
247 Thase ME, Simons AD, McGeary J, Cahalane JF, Hughes C, Harden T, et al. Relapse after cognitive behavior therapy of depression: Potential implications for longer courses of treatment. American Journal of Psychiatry. 1992;149(8):1046-52. [pmid: 1636804].
248 Thienhaus OJ, Margletta S, Bennett JA. A study of the clinical efficacy of maintenance ECT. J Clin Psychiatry. Apr. 1990;51(4):141-4. [pmid: 2324077].
249 Triggs WJ, McCoy KJM, Greer R, Rossi F, Bowers D, Kortenkamp S, et al. Effects of left frontal transcranial magnetic stimulation on depressed mood, cognition, and corticomotor threshold. Biological Psychiatry. Jun. 1999;45(11):1440-6. [pmid: 10356626].
250 Tsuchiyama K, Nagayama H, Yamada K, Isogawa K, Katsuragi S, Kiyota A. Predicting efficacy of electroconvulsive therapy in major depressive disorder. Psychiatry Clin Neurosci. Oct. 2005;59(5):546-50. [pmid: 16194256].
251 Turnier-Shea Y, Bruno R, Pridmore S. Daily and spaced treatment with transcranial magnetic stimulation in major depression: a pilot study. Aust N Z J Psychiatry. Sep. 2006;40(9):759-63. [pmid: 16911750].
252 Tutty S, Ludman EJ, Simon G. Feasibility and acceptability of a telephone psychotherapy program for depressed adults treated in primary care. General Hospital Psychiatry. Nov-Dec. 2005;27(6):400-10. [pmid: 16271654].
253 Udupa K, Sathyaprabha TN, Thirthalli J, Kishore KR, Raju TR, Gangadhar BN. Modulation of cardiac autonomic functions in patients with major depression treated with repetitive transcranial magnetic stimulation. J Affect Disord. Dec. 2007;104(1-3):231-6. [pmid: 17490754].
254 van Beusekom BS, van den Broek WW, Birkenhager TK. Long-term follow-up after successful electroconvulsive therapy for depression: a 4- to 8-year naturalistic follow-up study. J Ect. Mar. 2007;23(1):17-20. [pmid: 17435567].
255 van den Broek WW, de Lely A, Mulder PG, Birkenhager TK, Bruijn JA. Effect of antidepressant medication resistance on short-term response to electroconvulsive therapy. J Clin Psychopharmacol. Aug. 2004;24(4):400-3. [pmid: 15232331].
256 Vanelle JM, Loo H, Galinowski A, de Carvalho W, Bourdel MC, Brochier P, et al. Maintenance ECT in intractable manic-depressive disorders. Convuls Ther. Sep. 1994;10(3):195-205. [pmid: 7834256].
257 Vinar O. Tianeptine helps depressed patients resistant to reuptake inhibitors and/or IMAO. Homeostasis in Health and Disease. 1999;39(6):234-5.
258 Vlissides DN, Jenner FA. The response of endogenously and reactivity depressed patients to electroconvulsive therapy. Br J Psychiatry. Sep. 1982;141:239-42. [pmid: 7139205].
259 Warren EW, Groome DH. Memory test performance under three different waveforms of ECT for depression. Br J Psychiatry. Apr. 1984;144:370-5. [pmid: 6722398].
260 Watkins E, Scott J, Wingrove J, Rimes K, Bathurst N, Steiner H, et al. Rumination-focused cognitive behaviour therapy for residual depression: a case series. Behav Res Ther. Sep. 2007;45(9):2144-54. [pmid: 17367751].
261 Welch CA, Weiner RD, Weir D. Efficacy of ECT in the treatment of depression: Wave form and electrode placement considerations. Psychopharmacology bulletin. 1982;18(1):31-4. [pmid: 7146252].
262 Wesner RB, Winokur G. The influence of age on the natural history of unipolar depression when treated with electroconvulsive therapy. Eur Arch Psychiatry Neurol Sci. 1989;238(3):149-54. [pmid: 2721532].
263 Williams JH, O'Brien JT, Cullum S. Time course of response to electroconvulsive therapy in elderly depressed subjects. Int J Geriatr Psychiatry. May. 1997;12(5):563-6. [pmid: 9193966].
264 Wu L, Zou H, Zhou Q, Liu Z, Cheng B. Preemptive analgesia with butorphanol in psychotic patients following modified electroconvulsive therapy: A randomized controlled trial. Neural Regeneration Research. 2008;3(1):75-8.
265 Yildiz A, Mantar A, Simsek S, Onur E, Gokmen N, Fidaner H. Combination of pharmacotherapy with electroconvulsive therapy in prevention of depressive relapse: a pilot controlled trial. J ECT. Jun. 2010;26(2):104-10. [pmid: 19935091].
266 Zanardini R, Gazzoli A, Ventriglia M, Perez J, Bignotti S, Rossini PM, et al. Effect of repetitive transcranial magnetic stimulation on serum brain derived neurotrophic factor in drug resistant depressed patients. J Affect Disord. Mar. 2006;91(1):83-6. [pmid: 16448701].
267 Zielinski RJ, Roose SP, Devanand DP, Woodring S, Sackeim HA. Cardiovascular complications of ECT in depressed patients with cardiac disease. Am J Psychiatry. Jun. 1993;150(6):904-9. [pmid: 8494067].
268 Zimmerman M, Coryell W, Pfohl B, Corenthal C, Stangl D. ECT response in depressed patients with and without a DSM-III personality disorder. Am J Psychiatry. Aug. 1986;143(8):1030-2. [pmid: 3728718].
269 Zorumski CF, Rutherford JL, Burke WJ, Reich T. ECT in primary and secondary depression. J Clin Psychiatry. Jun. 1986;47(6):298-300. [pmid: 3711027].

## Wrong Population

1 Aarre TF, Dahl AA, Johansen JB, Kjonniksen I, Neckelmann D. Efficacy of repetitive transcranial magnetic stimulation in depression: a review of the evidence. Nord J Psychiatry. 2003;57(3):227-32. [pmid: 12775299].
2 Abbass Allan A, Hancock Jeffrey T, Henderson J, Kisely Steve R. Short-term psychodynamic psychotherapies for common mental disorders, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2006.
3 Adli M, Baethge C, Heinz A, Langlitz N, Bauer M. Is dose escalation of antidepressants a rational strategy after a medium-dose treatment has failed? A systematic review. Eur Arch Psychiatry Clin Neurosci. Dec. 2005;255(6):387-400. [pmid: 15868067].
4 Anderson B, Mishory A, Nahas Z, Borckardt JJ, Yamanaka K, Rastogi K, et al. Tolerability and safety of high daily doses of repetitive transcranial magnetic stimulation in healthy young men. Journal of ECT. 2006;22(1):49-53. [pmid: 16633208].
5 Anderson IM, Delvai NA, Ashim B, Ashim S, Lewin C, Singh V, et al. Adjunctive fast repetitive transcranial magnetic stimulation in depression. Br J Psychiatry. Jun. 2007;190:533-4. [pmid: 17541116].
6 Armitage R, Husain M, Hoffmann R, Rush AJ. The effects of vagus nerve stimulation on sleep EEG in depression: a preliminary report. J Psychosom Res. May. 2003;54(5):475-82. [pmid: 12726905].
7 Avery DH, Claypoole K, Robinson L, Neumaier JF, Dunner DL, Scheele L, et al. Repetitive transcranial magnetic stimulation in the treatment of medication-resistant depression: preliminary data. J Nerv Ment Dis. Feb. 1999;187(2):114-7. [pmid: 10067953].
8 Baeken C, Leyman L, De Raedt R, Vanderhasselt MA, D'Haenen H. Lack of impact of repetitive high frequency transcranial magnetic stimulation on mood in healthy female subjects. Journal of Affective Disorders. Jan. 2006;90(1):63-6. [pmid: 16325919].
9 Bagadia VN, Shah LP, Pradhan PV. Evaluation of cognitive effects of ECT (preliminary observations). Indian J Psychiatry. 1981;23(4):324-9. [pmid: 22058556].
10 Bagby RM, Quilty LC, Segal ZV, McBride CC, Kennedy SH, Costa PT. Personality and differential treatment response in major depression: a randomized controlled trial comparing cognitive-behavioural therapy and pharmacotherapy. Can J Psychiatry. Jun. 2008;53(6):361-70. [pmid: 18616856].
11 Baldomero EB, Ubago JG, Cercos CL, Ruiloba JV, Calvo CG, Lopez RP. Venlafaxine extended release versus conventional antidepressants in the remission of depressive disorders after previous antidepressant failure: ARGOS study. Depress Anxiety. Aug. 10. 2005;22(2):68-76. [pmid: 16094658].
12 Bares M, Kopecek M, Novak T, Stopkova P, Sos P, Kozeny J, et al. Low frequency (1Hz), right prefrontal repetitive transcranial magnetic stimulation (rTMS) compared with venlafaxine ER in the treatment of resistant depression: A double-blind, single-centre, randomized study. Journal of Affective Disorders. 11. 2009;118(1):94-100. [pmid: 19249105].
13 Bauer M, Adli M, Baethge C, Berghofer A, Sasse J, Heinz A, et al. Lithium augmentation therapy in refractory depression: clinical evidence and neurobiological mechanisms. Can J Psychiatry. Aug. 2003;48(7):440-8. [pmid: 12971013].
14 Bauer M, Dopfmer S. Lithium augmentation in treatment-resistant depression: meta-analysis of placebo-controlled studies. J Clin Psychopharmacol. Oct. 1999;19(5):427-34. [pmid: 10505584].
15 Bauer M, Forsthoff A, Baethge C, Adli M, Berghofer A, Dopfmer S, et al. Lithium augmentation therapy in refractory depression-update 2002. Eur Arch Psychiatry Clin Neurosci. Jun. 2003;253(3):132-9. [pmid: 12904977].
16 Bauer M, Tharmanathan P, Volz HP, Moeller HJ, Freemantle N. The effect of venlafaxine compared with other antidepressants and placebo in the treatment of major depression: a meta-analysis. Eur Arch Psychiatry Clin Neurosci. Apr. 2009;259(3):172-85. [pmid: 19165525].
17 Baumann P, Nil R, Souche A, Montaldi S, Baettig D, Lambert S, et al. A double-blind, placebo-controlled study of citalopram with and without lithium in the treatment of therapy-resistant depressive patients: a clinical, pharmacokinetic, and pharmacogenetic investigation. J Clin Psychopharmacol. Aug. 1996;16(4):307-14. [pmid: 8835706].
18 Birkenhager TK, van den Broek WW, Mulder PG, Bruijn JA, Moleman P. Efficacy and tolerability of tranylcypromine versus phenelzine: a double-blind study in antidepressant-refractory depressed inpatients. J Clin Psychiatry. Nov. 2004;65(11):1505-10. [pmid: 15554763].
19 Black DW, Winokur G, Mohandoss E, Woolson RF, Nasrallah A. Does treatment influence mortality in depressives? A follow-up of 1076 patients with major affective disorders. Annals of Clinical Psychiatry. 1989;1(3):165-73.
20 Black DW, Winokur G, Nasrallah A. Treatment and outcome in secondary depression: a naturalistic study of 1087 patients. J Clin Psychiatry. Nov. 1987;48(11):438-41. [pmid: 3680184].
21 Black DW, Winokur G, Nasrallah A. The treatment of depression: electroconvulsive therapy v antidepressants: a naturalistic evaluation of 1,495 patients. Compr Psychiatry. Mar-Apr. 1987;28(2):169-82. [pmid: 3829660].
22 Blackburn IM, Moore RG. Controlled acute and follow-up trial of cognitive therapy and pharmacotherapy in out-patients with recurrent depression. Br J Psychiatry. Oct. 1997;171:328-34. [pmid: 9373420].
23 Boggio PS, Bermpohl F, Vergara AO, Muniz ALCR, Nahas FH, Leme PB, et al. Go-no-go task performance improvement after anodal transcranial DC stimulation of the left dorsolateral prefrontal cortex in major depression. Journal of Affective Disorders. Aug. 2007;101(1):91-8. [pmid: 17166593].
24 Boggio PS, Fregni F, Bermpohl F, Mansur CG, Rosa M, Rumi DO, et al. Effect of repetitive TMS and fluoxetine on cognitive function in patients with Parkinson's disease and concurrent depression. Mov Disord. Sep. 2005;20(9):1178-84. [pmid: 15895421].
25 Bonne O, Krausz Y, Shapira B, Bocher M, Karger H, Gorfine M, et al. Increased cerebral blood flow in depressed patients responding to electroconvulsive therapy. Journal of Nuclear Medicine. 1996;37(7):1075-80. [pmid: 8965172].
26 Bradvik L, Berglund M. Long-term treatment and suicidal behavior in severe depression: ECT and antidepressant pharmacotherapy may have different effects on the occurrence and seriousness of suicide attempts. Depress Anxiety. 2006;23(1):34-41. [pmid: 16315268].
27 Brakemeier EL, Wilbertz G, Rodax S, Danker-Hopfe H, Zinka B, Zwanzger P, et al. Patterns of response to repetitive transcranial magnetic stimulation (rTMS) in major depression: replication study in drug-free patients. J Affect Disord. May. 2008;108(1-2):59-70. [pmid: 17963846].
28 Brandon S, Cowley P, McDonald C, Neville P, Palmer R, Wellstood-Eason S. Electroconvulsive therapy: results in depressive illness from the Leicestershire trial. Br Med J (Clin Res Ed). Jan. 7. 1984;288(6410):22-5.
29 Brent D, Emslie G, Clarke G, Wagner KD, Asarnow JR, Keller M, et al. Switching to another SSRI or to venlafaxine with or without cognitive behavioral therapy for adolescents with SSRI-resistant depression: The TORDIA randomized controlled trial. Journal of the American Medical Association. Feb. 2008;299(8):901-13. [pmid: 18314433].
30 Browne M, Lapierre YD, Hrdina PD, Horn E. Lithium as an adjunct in the treatment of major depression. Int Clin Psychopharmacol. Apr. 1990;5(2):103-10. [pmid: 2116474].
31 Bschor T, Baethge C. No evidence for switching the antidepressant: systematic review and meta-analysis of RCTs of a common therapeutic strategy (Provisional abstract). Acta Psychiatrica Scandinavica. 2010:174-9.
32 Bschor T, Bauer M. Efficacy and mechanisms of action of lithium augmentation in refractory major depression. Curr Pharm Des. 2006;12(23):2985-92. [pmid: 16918427].
33 Burke MJ, Husain MM. Concomitant use of vagus nerve stimulation and electroconvulsive therapy for treatment-resistant depression. J Ect. Sep. 2006;22(3):218-22. [pmid: 16957540].
34 Burt T, Lisanby SH, Sackeim HA. Neuropsychiatric applications of transcranial magnetic stimulation: A meta-analysis. International Journal of Neuropsychopharmacology. 2002;5(1):73-103. [pmid: 12057034].
35 Carney RM, Blumenthal JA, Freedland KE, Youngblood M, Veith RC, Burg MM, et al. Depression and late mortality after myocardial infarction in the Enhancing Recovery in Coronary Heart Disease (ENRICHD) study. Psychosom Med. Jul-Aug. 2004;66(4):466-74. [pmid: 15272090].
36 Carpenter LL, Yasmin S, Price LH. A double-blind, placebo-controlled study of antidepressant augmentation with mirtazapine. Biol Psychiatry. Jan. 15. 2002;51(2):183-8. [pmid: 11822997].
37 Carretero B, Martin MJ, Juan A, Pradana ML, Martin B, Carral M, et al. Low-frequency transcranial magnetic stimulation in patients with fibromyalgia and major depression. Pain Med. May-Jun. 2009;10(4):748-53. [pmid: 19460131].
38 Cassano GB, Jori MC. Efficacy and safety of amisulpride 50 mg versus paroxetine 20 mg in major depression: A randomized, double-blind, parallel group study. International Clinical Psychopharmacology. 2002;17(1):27-32. [pmid: 11800503].
39 Chistyakov AV, Kaplan B, Rubichek O, Kreinin I, Koren D, Feinsod M, et al. Antidepressant effects of different schedules of repetitive transcranial magnetic stimulation vs. clomipramine in patients with major depression: relationship to changes in cortical excitability. Int J Neuropsychopharmacol. Jun. 2005;8(2):223-33. [pmid: 15569397].
40 Cipriani A, Smith K, Burgess S, Carney S, Goodwin G, Geddes J. Lithium versus antidepressants in the long-term treatment of unipolar affective disorder. Cochrane Database Syst Rev. 2006;(4). CD003492.
41 Coffey CE, Lucke J, Weiner RD, Krystal AD, Aque M. Seizure threshold in electroconvulsive therapy (ECT) II. The anticonvulsant effect of ECT. Biological Psychiatry. 1995;37(11):777-88. [pmid: 7647162].
42 Conca A, Koppi S, König P, Swoboda E, Krecke N. Transcranial magnetic stimulation: a novel antidepressive strategy?. Neuropsychobiology. 1996;34(4):204-7. [pmid: 9121622].
43 Cook IA, Leuchter AF, Witte E, Abrams M, Uijtdehaage SH, Stubbeman W, et al. Neurophysiologic predictors of treatment response to fluoxetine in major depression. Psychiatry Res. Mar. 22. 1999;85(3):263-73. [pmid: 10333379].
44 Couturier JL. Efficacy of rapid-rate repetitive transcranial magnetic stimulation in the treatment of depression: A systematic review and meta-analysis. J Psychiatry Neurosci. 2005;30(2):83-90. [pmid: 15798783].
45 Craig TJ, Grossman S, Bromet EJ, Fochtmann LJ, Carlson GA. Medication use patterns and two-year outcome in first-admission patients with major depressive disorder with psychotic features. Compr Psychiatry. Nov-dec. 2007;48(6):497-503. [pmid: 17954133].
46 Crossley NA, Bauer M. Acceleration and augmentation of antidepressants with lithium for depressive disorders: two meta-analyses of randomized, placebo-controlled trials. J Clin Psychiatry. Jun. 2007;68(6):935-40. [pmid: 17592920].
47 Dannon PN, Schreiber S, Dolberg OT, Shemer L, Grunhaus L. Transcranial magnetic stimulation is effective in the treatment of relapse of depression. International Journal of Psychiatry in Clinical Practice. 2000;4(3):223-6.
48 Dejonge P, Honig A, Van Melle JP, Schene AH, Kuyper AMG, Tulner D, et al. Nonresponse to treatment for depression following myocardial infarction: Association with subsequent cardiac events. The American Journal of Psychiatry. 09. 2007;164(9):1371-8. [pmid: 17728422].
49 Demirtas-Tatlidede A, Mechanic-Hamilton D, Press DZ, Pearlman C, Stern WM, Thall M, et al. An open-label, prospective study of repetitive transcranial magnetic stimulation (rTMS) in the long-term treatment of refractory depression: reproducibility and duration of the antidepressant effect in medication-free patients. J Clin Psychiatry. Jun. 2008;69(6):930-4. [pmid: 18505308].
50 DeRubeis RJ, Feeley M. Determinants of change in cognitive therapy for depression. Cognitive Therapy and Research. 1990;14(5):469-82.
51 DeRubeis RJ, Gelfand LA, Tang TZ, Simons AD. Medications versus cognitive behavior therapy for severely depressed outpatients: Mega-analysis of four randomized comparisons. American Journal of Psychiatry. 1999;156(7):1007-13. [pmid: 10401443].
52 Devinsky O, Duchowny MS. Seizures after convulsive therapy: a retrospective case survey. Neurology. Jul. 1983;33(7):921-5. [pmid: 6683376].
53 Dimitriou EC, Dimitriou CE. Buspirone augmentation of antidepressant therapy. J Clin Psychopharmacol. Dec. 1998;18(6):465-9. [pmid: 9864079].
54 Dinan TG, Barry S. A comparison of electroconvulsive therapy with a combined lithium and tricyclic combination among depressed tricyclic nonresponders. Acta Psychiatr Scand. Jul. 1989;80(1):97-100. [pmid: 2504034].
55 Dorr AE, Debonnel G. Effect of vagus nerve stimulation on serotonergic and noradrenergic transmission. Journal of Pharmacology and Experimental Therapeutics. 2006;318(2):890-8. [pmid: 16690723].
56 Ekers D, Richards D, Gilbody S. A meta-analysis of randomized trials of behavioural treatment of depression. Psychol Med. May. 2008;38(5):611-23. [pmid: 17903337].
57 Evans MD, Hollon SD, DeRubeis RJ, Piasecki JM, Grove WM, Garvey MJ, et al. Differential relapse following cognitive therapy and pharmacotherapy for depression. Archives of General Psychiatry. 1992;49(10):802-8. [pmid: 1417433].
58 Evers S, Hangst K, Pecuch PW. The impact of repetitive transcranial magnetic stimulation on pituitary hormone levels and cortisol in healthy subjects. Journal of Affective Disorders. Sep. 2001;66(1):83-8. [pmid: 11532537].
59 Fava M, Alpert J, Nierenberg A, Lagomasino I, Sonawalla S, Tedlow J, et al. Double-blind study of high-dose fluoxetine versus lithium or desipramine augmentation of fluoxetine in partial responders and nonresponders to fluoxetine. Journal of Clinical Psychopharmacology. 08. 2002;22(4):379-87. [pmid: 12172337].
60 Fava M, Rosenbaum JF, McGrath PJ, Stewart JW, Amsterdam JD, Quitkin FM. Lithium and tricyclic augmentation of fluoxetine treatment for resistant major depression: a double-blind, controlled study. Am J Psychiatry. Sep. 1994;151(9):1372-4. [pmid: 8067495].
61 Feinsod M, Kreinin B, Chistyakov A, Klein E. Preliminary evidence for a beneficial effect of low-frequency, repetitive transcranial magnetic stimulation in patients with major depression and schizophrenia. Depression and Anxiety. 1998;7(2):65-8. [pmid: 9614593].
62 Ferreri M, Lavergne F, Berlin I, Payan C, Puech AJ. Benefits from mianserin augmentation of fluoxetine in patients with major depression non-responders to fluoxetine alone. Acta Psychiatr Scand. Jan. 2001;103(1):66-72. [pmid: 11202131].
63 Fink M, Rush AJ, Knapp R, Rasmussen K, Mueller M, Rummans TA, et al. DSM melancholic features are unreliable predictors of ECT response: a CORE publication. J Ect. Sep. 2007;23(3):139-46. [pmid: 17804986].
64 Flint AJ, Rifat SL. The treatment of psychotic depression in later life: a comparison of pharmacotherapy and ECT. Int J Geriatr Psychiatry. Jan. 1998;13(1):23-8. [pmid: 9489577].
65 Flint AJ, Rifat SL. Two-year outcome of psychotic depression in late life. Am J Psychiatry. Feb. 1998;155(2):178-83. [pmid: 9464195].
66 Floyd M, Scogin F, McKendree-Smith NL, Floyd DL, Rokke PD. Cognitive therapy for depression: a comparison of individual psychotherapy and bibliotherapy for depressed older adults. Behavior Modification. 2004;28(2):297-318. [pmid: 14997954].
67 Freeman CP, Weeks D, Kendell RE. ECT: II: patients who complain. Br J Psychiatry. Jul. 1980;137:17-25. [pmid: 7459536].
68 Fregni F, Ono CR, Santos CM, Bermpohl F, Buchpiguel C, Barbosa ER, et al. Effects of antidepressant treatment with rTMS and fluoxetine on brain perfusion in PD. Neurology. Jun. 13. 2006;66(11):1629-37. [pmid: 16769932].
69 Fregni F, Santos CM, Myczkowski ML, Rigolino R, Gallucci-Neto J, Barbosa ER, et al. Repetitive transcranial magnetic stimulation is as effective as fluoxetine in the treatment of depression in patients with Parkinson's disease. J Neurol Neurosurg Psychiatry. Aug. 2004;75(8):1171-4. [pmid: 15258224].
70 Gallagher DE, Thompson LW. Treatment of major depressive disorder in older adult outpatients with brief psychotherapies. Psychotherapy. 1982;19(4):482-90.
71 Gangadhar BN, Kapur RL, Kalyanasundaram S. Comparison of electroconvulsive therapy with imipramine in endogenous depression: a double blind study. Br J Psychiatry. Oct. 1982;141:367-71. [pmid: 6756530].
72 Garcia-Toro M, Pascual-Leone A, Romera M, Gonzalez A, MicÃ³ J, Ibarra O, et al. Prefrontal repetitive transcranial magnetic stimulation as add on treatment for depression. Journal of Neurology, Neurosurgery & Psychiatry. Oct. 2001;71(4):546-8.
73 Geddes J, Carney S, Cowen P, Goodwin G, Rogers R, Dearness K, et al. Efficacy and safety of electroconvulsive therapy in depressive disorders: a systematic review and meta-analysis. Lancet. Mar. 8. 2003;361(9360):799-808. [pmid: 12642045].
74 George MS, Nahas Z, Molloy M, Speer AM, Oliver NC, Li XB, et al. A controlled trial of daily left prefrontal cortex TMS for treating depression. Biological Psychiatry. Nov. 2000;48(10):962-70. [pmid: 11082469].
75 Gloaguen V, Cottraux J, Cucherat M, Blackburn IM. A meta-analysis of the effects of cognitive therapy in depressed patients. J Affect Disord. Apr. 1998;49(1):59-72. [pmid: 9574861].
76 Gross M, Nakamura L, Pascual-Leone A, Fregni F. Has repetitive transcranial magnetic stimulation (rTMS) treatment for depression improved? A systematic review and meta-analysis comparing the recent vs. the earlier rTMS studies. Acta Psychiatr Scand. Sep. 2007;116(3):165-73. [pmid: 17655557].
77 Grunhaus L, Dolberg OT, Polak D, Dannon PN. Monitoring the response to rTMS in depression with visual analog scales. Human Psychopharmacology: Clinical and Experimental. Oct. 2002;17(7):349-52. [pmid: 12415554].
78 Grunhaus L, Polak D, Amiaz R, Dannon PN. Motor-evoked potential amplitudes elicited by transcranial magnetic stimulation do not differentiate between patients and normal controls. Int J Neuropsychopharmacol. Dec. 2003;6(4):371-8. [pmid: 14604452].
79 Hansen PE, Videbech P, Clemmensen K, Sturlason R, Jensen HM, Vestergaard P. Repetitive transcranial magnetic stimulation as add-on antidepressant treatment. The applicability of the method in a clinical setting. Nord J Psychiatry. 2004;58(6):455-7. [pmid: 16195088].
80 Hausmann A, Kemmler G, Walpoth M, Mechtcheriakov S, Kramer-Reinstadler K, Lechner T, et al. No benefit derived from repetitive transcranial magnetic stimulation in depression: A prospective, single centre, randomised, double blind, sham controlled “add on” trial. Journal of Neurology, Neurosurgery and Psychiatry. 2004;75(2):320-2.
81 Hausmann A, Pascual-Leone A, Kemmler G, Rupp CI, Lechner-Schoner T, Kramer-Reinstadler K, et al. No deterioration of cognitive performance in an aggressive unilateral and bilateral antidepressant rTMS add-on trial. Journal of Clinical Psychiatry. Jun. 2004;65(6):772-82. [pmid: 15291654].
82 Heijnen WT, van den Broek WW, Birkenhager TK. Treatment failure with a tricyclic antidepressant followed by lithium addition and response to subsequent electroconvulsive therapy. J Clin Psychiatry. Dec. 2008;69(12):1887-91. [pmid: 19014754].
83 Henry ME, Schmidt ME, Matochik JA, Stoddard EP, Potter WZ. The effects of ECT on brain glucose: a pilot FDG PET study. J Ect. Mar. 2001;17(1):33-40. [pmid: 11281513].
84 Henry TR, Votaw JR, Pennell PB, Epstein CM, Bakay RAE, Faber TL, et al. Acute blood flow changes and efficacy of vagus nerve stimulation in partial epilepsy. Neurology. 1999;52(6):1166-73. [pmid: 10214738].
85 Herrmann LL, Ebmeier KP. Factors modifying the efficacy of transcranial magnetic stimulation in the treatment of depression: a review (Structured abstract). Journal of Clinical Psychiatry. 2006;(12):1870-6. [pmid: 17194264].
86 Hoeppner J, Padberg F, Domes G, Zinke A, Herpertz SC, Grossheinrich N, et al. Influence of repetitive transcranial magnetic stimulation on psychomotor symptoms in major depression. Eur Arch Psychiatry Clin Neurosci. Apr. 2010;260(3):197-202. [pmid: 19680706].
87 Holtzheimer PE 3rd, Russo J, Avery DH. A meta-analysis of repetitive transcranial magnetic stimulation in the treatment of depression. Psychopharmacology bulletin. 2001;35(4):149-69. [pmid: 12397863].
88 Höppner J, Schulz M, Irmisch G, Mau R, Schläfke D, Richter J. Antidepressant efficacy of two different rTMS procedures: High frequency over left versus low frequency over right prefrontal cortex compared with sham stimulation. European Archives of Psychiatry and Clinical Neuroscience. 2003;253(2):103-9. [pmid: 12799750].
89 Ikeji OC, Ohaeri JU, Osahon RO, Agidee RO. Naturalistic comparative study of outcome and cognitive effects of unmodified electro-convulsive therapy in schizophrenia, mania and severe depression in Nigeria. East Afr Med J. Nov. 1999;76(11):644-50. [pmid: 10734527].
90 Janakiramaiah N, Gangadhar BN, Naga Venkatesha, Murthy PJ, Harish MG, Subbakrishna DK, Vedamurthachar A. Antidepressant efficacy of Sudarshan Kriya Yoga (SKY) in melancholia: a randomized comparison with electroconvulsive therapy (ECT) and imipramine. J Affect Disord. Jan-Mar. 2000;57(1-3):255-9. [pmid: 10708840].
91 Janicak PG, Dowd SM, Martis B, Alam D, Beedle D, Krasuski J, et al. Repetitive transcranial magnetic stimulation versus electroconvulsive therapy for major depression: preliminary results of a randomized trial. Biol Psychiatry. Apr. 15. 2002;51(8):659-67. [pmid: 11955466].
92 Joffe RT, Singer W, Levitt AJ, MacDonald C. A placebo-controlled comparison of lithium and triiodothyronine augmentation of tricyclic antidepressants in unipolar refractory depression. Arch Gen Psychiatry. May. 1993;50(5):387-93. [pmid: 8489327].
93 Joseph MH, Risby D, Crow TJ, Deakin JF, Johnstone EC, Lawler P. MHPG excretion in endogenous depression: relationship to clinical state and the effects of ECT. Psychopharmacology (Berl). 1985;87(4):442-8. [pmid: 2867575].
94 Kalb R, Ellinger K, Reulbach U. Improvement in response times for simple and complex tasks after electroconvulsive therapy. Prog Neuropsychopharmacol Biol Psychiatry. May. 2003;27(3):459-65. [pmid: 12691781].
95 Kapstan A, Yaroslavsky Y, Applebaum J, Belmaker RH, Grisaru N. Right prefrontal TMS versus sham treatment of mania: A controlled study. Bipolar Disorders. Feb. 2003;5(1):36-9.
96 Katona CLE, Abou-Saleh MT, Harrison DA, Nairac BA. Placebo-controlled trial of lithium augmentation of fluoxetine and lofepramine. British Journal of Psychiatry. 01. 1995;166:80-6. [pmid: 7894881].
97 Keitner GI, Garlow SJ, Ryan CE, Ninan PT, Solomon DA, Nemeroff CB, et al. A randomized, placebo-controlled trial of risperidone augmentation for patients with difficult-to-treat unipolar, non-psychotic major depression, Journal of Psychiatric Research. Netherlands. Elsevier Science. 2009:205-14.
98 Keller MB, Lavori PW, Mueller TI, Endicott J, Coryell W, Hirschfeld RMA, et al. Time to recovery, chronicity, and levels of psychopathology in major depression: A 5-year prospective follow-up of 431 subjects. Archives of General Psychiatry. 1992;49(10):809-16. [pmid: 1417434].
99 Keller MB, McCullough JP, Klein DN, Arnow B, Dunner DL, Gelenberg AJ, et al. A comparison of nefazodone, the cognitive behavioral-analysis system of psychotherapy, and their combination for the treatment of chronic depression. New England Journal of Medicine. 2000;342(20):1462-70. [pmid: 10816183].
100 Kellner CH, Knapp RG, Petrides G, Rummans TA, Husain MM, Rasmussen K, et al. Continuation electroconvulsive therapy vs pharmacotherapy for relapse prevention in major depression: a multisite study from the Consortium for Research in Electroconvulsive Therapy (CORE). Arch Gen Psychiatry. 2006:1337-44.
101 Kennedy SH, McCann SM, Masellis M, McIntyre RS, Raskin J, McKay G, et al. Combining bupropion SR with venlafaxine, paroxetine, or fluoxetine: a preliminary report on pharmacokinetic, therapeutic, and sexual dysfunction effects. J Clin Psychiatry. Mar. 2002;63(3):181-6. [pmid: 11926715].
102 Kennedy SH, Segal ZV, Cohen NL, Levitan RD, Gemar M, Bagby RM. Lithium carbonate versus cognitive therapy as sequential combination treatment strategies in partial responders to antidepressant medication: An exploratory trial. Journal of Clinical Psychiatry. Apr. 2003;64(4):439-44. [pmid: 12716247].
103 Khalid N, Atkins M, Tredget J, Giles M, Champney-Smith K, Kirov G. The effectiveness of electroconvulsive therapy in treatment-resistant depression: a naturalistic study. J Ect. Jun. 2008;24(2):141-5. [pmid: 18580559].
104 Kho KH, van Vreeswijk MF, Simpson S, Zwinderman AH. A meta-analysis of electroconvulsive therapy efficacy in depression. J Ect. Sep. 2003;19(3):139-47. [pmid: 12972983].
105 Kito S, Fujita K, Koga Y. Regional cerebral blood flow changes after low-frequency transcranial magnetic stimulation of the right dorsolateral prefrontal cortex in treatment-resistant depression. Neuropsychobiology. 2008;58(1):29-36. [pmid: 18781088].
106 Klein E, Kreinin I, Chistyakov A, Koren D, Mecz L, Marmur S, et al. Therapeutic efficacy of right prefrontal slow repetitive transcranial magnetic stimulation in major depression: a double-blind controlled study. Arch Gen Psychiatry. Apr. 1999;56(4):315-20. [pmid: 10197825].
107 Kocsis JH, Friedman RA, Markowitz JC, Leon AC, Miller NL, Gniwesch L, et al. Maintenance therapy for chronic depression: A controlled clinical trial of desipramine. Archives of General Psychiatry. 1996;53(9):769-76. [pmid: 8792753].
108 Koerselman F, Laman DM, van Duijn H, van Duijn MA, Willems MA. A 3-month, follow-up, randomized, placebo-controlled study of repetitive transcranial magnetic stimulation in depression. J Clin Psychiatry. Oct. 2004;65(10):1323-8. [pmid: 15491234].
109 Kok RM, Vink D, Heeren TJ, Nolen WA. Lithium augmentation compared with phenelzine in treatment-resistant depression in the elderly: an open, randomized, controlled trial. J Clin Psychiatry. Aug. 2007;68(8):1177-85. [pmid: 17854241].
110 Kolbinger HM, Höflich G, Hufnagel A, Möller HJ, Kasper S. Transcranial magnetic stimulation (TMS) in the treatment of major depression: A pilot study. Human Psychopharmacology: Clinical and Experimental. Jul-Aug. 1995;10(4):305-10.
111 Kozel FA, George MS. Meta-analysis of left prefrontal repetitive transcranial magnetic stimulation (rTMS) to treat depression. J Psychiatr Pract. 2002;8(5):270-5. [pmid: 15985889].
112 Kozel FA, Nahas Z, deBrux C, Molloy M, Lorberbaum JP, Bohning D, et al. How coil-cortex distance relates to age, motor threshold, and antidepressant response to repetitive transcranial magnetic stimulation. Journal of Neuropsychiatry & Clinical Neurosciences. Sum. 2000;12(3):376-84. [pmid: 10956572].
113 Kroessler D. Relative efficacy rates for therapies of delusional depression. Convulsive Therapy. 1985;1(3):173-82. [pmid: 11940821].
114 Laidlaw K, Davidson K, Toner H, Jackson G, Clark S, Law J, et al. A randomised controlled trial of cognitive behaviour therapy vs treatment as usual in the treatment of mild to moderate late life depression. Int J Geriatr Psychiatry. Aug. 2008;23(8):843-50. [pmid: 18311844].
115 Lam RW, Chan P, Wilkins-Ho M, Yatham LN. Repetitive Transcranial Magnetic Stimulation for Treatment-Resistant Depression: A Systematic Review and Metaanalysis. Canadian journal of psychiatry Revue canadienne de psychiatrie. 2008;53(9):621. [pmid: 18801225].
116 Landén M, Björling Gr, Agren H, Fahlén T. A randomized, double-blind, placebo-controlled trial of busiprone in combination with an S SRI in patients with treatment-refractory depression. Journal of Clinical Psychiatry. 12. 1998;59(12):664-8. [pmid: 9921700].
117 Landreville P, Bissonnette L. Effects of cognitive bibliotherapy for depressed older adults with a disability. Clinical Gerontologist. 1997;17(4):35-55.
118 Langguth B, Wiegand R, Kharraz A, Landgrebe M, Marienhagen J, Frick U, et al. Pre-treatment anterior cingulate activity as a predictor of antidepressant response to repetitive transcranial magnetic stimulation (rTMS). Neuro Endocrinol Lett. Oct. 2007;28(5):633-8. [pmid: 17984932].
119 Lefaucheur JP, Lucas B, Andraud F, Hogrel JY, Bellivier F, Del Cul A, et al. Interhemispheric asymmetry of motor corticospinal excitability in major depression studied by transcranial magnetic stimulation. J Psychiatr Res. Apr. 2008;42(5):389-98. [pmid: 17449060].
120 Leichsenring F, Rabung S. Effectiveness of long-term psychodynamic psychotherapy: a meta-analysis. JAMA. 2008/10/02. 2008:1551-65.
121 Leykin Y, Amsterdam JD, DeRubeis RJ, Gallop R, Shelton RC, Hollon SD. Progressive resistance to a selective serotonin reuptake inhibitor but not to cognitive therapy in the treatment of major depression. J Consult Clin Psychol. Apr. 2007;75(2):267-76. [pmid: 17469884].
122 Licht RW, Qvitzau S. Treatment strategies in patients with major depression not responding to first-line sertraline treatment. A randomised study of extended duration of treatment, dose increase or mianserin augmentation. Psychopharmacology (Berl). May. 2002;161(2):143-51. [pmid: 11981594].
123 Lincoln NB, Flannaghan T. Cognitive behavioral psychotherapy for depression following stroke: A randomized controlled trial. Stroke. 2003;34(1):111-5. [pmid: 12511760].
124 Linssen AC, Zitman FG. Patient evaluation of a cognitive behavioral group program for patients with chronic low back pain. Social Science & Medicine. 1984;19(12):1361-5. [pmid: 6241749].
125 Lisanby SH, Sampson S, Husain MM, Petrides G, Knapp RG, McCall V, et al. Toward individualized post-electroconvulsive therapy care: piloting the Symptom-Titrated, Algorithm-Based Longitudinal ECT (STABLE) intervention. Journal of ECT. Sep. 2008;24(3):179-82. [pmid: 18708943].
126 Loo C, Mitchell P, Sachdev P, McDarmont B, Parker G, Gandevia S. Double-blind controlled investigation of transcranial magnetic stimulation for the treatment of resistant major depression. American Journal of Psychiatry. Jun. 1999;156(6):946-8. [pmid: 10360138].
127 Loo C, Sachdev P, Elsayed H, McDarmont B, Mitchell P, Wilkinson M, et al. Effects of a 2- to 4-week course of repetitive transcranial magnetic stimulation (rTMS) on neuropsychologic functioning, electroencephalogram, and auditory threshold in depressed patients. Biol Psychiatry. Apr. 1. 2001;49(7):615-23. [pmid: 11297719].
128 Loo CK, Mitchell PB, Croker VM, Malhi GS, Wen W, Gandevia SC, et al. Double-blind controlled investigation of bilateral prefrontal transcranial magnetic stimulation for the treatment of resistant major depression. Psychol Med. Jan. 2003;33(1):33-40. [pmid: 12537034].
129 Loo CK, Mitchell PB, McFarquhar TF, Malhi GS, Sachdev PS. A sham-controlled trial of the efficacy and safety of twice-daily rTMS in major depression. Psychol Med. Mar. 2007;37(3):341-9. [pmid: 17176505].
130 Lyketsos CG, DelCampo L, Steinberg M, Miles Q, Steele CD, Munro C, et al. Treating depression in Alzheimer disease: efficacy and safety of sertraline therapy, and the benefits of depression reduction: the DIADS. Archives of General Psychiatry. 2003;60(7):737-46. [pmid: 12860778].
131 Maes M, Libbrecht I, van Hunsel F, Campens D, Meltzer HY. Pindolol and mianserin augment the antidepressant activity of fluoxetine in hospitalized major depressed patients, including those with treatment resistance. J Clin Psychopharmacol. Apr. 1999;19(2):177-82. [pmid: 10211920].
132 Maihofner C, Ropohl A, Reulbach U, Hiller M, Elstner S, Kornhuber J, et al. Effects of repetitive transcranial magnetic stimulation in depression: a magnetoencephalographic study. Neuroreport. Nov. 7. 2005;16(16):1839-42. [pmid: 16237338].
133 Marangell LB, Suppes T, Zboyan HA, Prashad SJ, Fischer G, Snow D, et al. A 1-year pilot study of vagus nerve stimulation in treatment-resistant rapid-cycling bipolar disorder. J Clin Psychiatry. Feb. 2008;69(2):183-9. [pmid: 18211128].
134 Marano CM, Phatak P, Vemulapalli UR, Sasan A, Nalbandyan MR, Ramanujam S, et al. Increased plasma concentration of brain-derived neurotrophic factor with electroconvulsive therapy: a pilot study in patients with major depression. J Clin Psychiatry. Apr. 2007;68(4):512-7. [pmid: 17474805].
135 Martin JL, Barbanoj MJ, Schlaepfer TE, Thompson E, Perez V, Kulisevsky J. Repetitive transcranial magnetic stimulation for the treatment of depression. Systematic review and meta-analysis. Br J Psychiatry. Jun. 2003;182:480-91. [pmid: 12777338].
136 McCall WV, Prudic J, Olfson M, Sackeim H. Health-related quality of life following ECT in a large community sample. J Affect Disord. Feb. 2006;90(2-3):269-74. [pmid: 16412519].
137 McGrath PJ, Stewart JW, Nunes EV, Ocepek-Welikson K, Rabkin JG, Quitkin FM, et al. A double-blind crossover trial of imipramine and phenelzine for outpatients with treatment-refractory depression. Am J Psychiatry. Jan. 1993;150(1):118-23. [pmid: 8417553].
138 Menkes DL, Bodnar P, Ballesteros RA, Swenson MR. Right frontal lobe slow frequency repetitive transcranial magnetic stimulation (SF r-TMS) is an effective treatment for depression: A case-control pilot study of safety and efficacy. Journal of Neurology, Neurosurgery & Psychiatry. Jul. 1999;67(1):113-5.
139 Mingli H, Zhengtian G, Xinyi W, Xiaoping T. Effects of repetitive transcranial magnetic stimulation on hypothalamic-pituitary-adrenal axis of patients with depression. Journal of Medical Colleges of PLA. December. 2009;24(6):337-45.
140 Mitchell AJ, Subramaniam H. Prognosis of depression in old age compared to middle age: a systematic review of comparative studies. Am J Psychiatry. Sep. 2005;162(9):1588-601. [pmid: 16135616].
141 Mogg A, Pluck G, Eranti SV, Landau S, Purvis R, Brown RG, et al. A randomized controlled trial with 4-month follow-up of adjunctive repetitive transcranial magnetic stimulation of the left prefrontal cortex for depression. Psychol Med. Mar. 2008;38(3):323-33. [pmid: 17935639].
142 Moller AL, Hjaltason O, Ivarsson O, Stefansson SB. The effects of repetitive transcranial magnetic stimulation on depressive symptoms and the P(300) event-related potential. Nord J Psychiatry. 2006;60(4):282-5. [pmid: 16923636].
143 Mosimann UP, Schmitt W, Greenberg BD, Kosel M, Muri RM, Berkhoff M, et al. Repetitive transcranial magnetic stimulation: a putative add-on treatment for major depression in elderly patients. Psychiatry Res. Apr. 30. 2004;126(2):123-33. [pmid: 15123391].
144 Münchau A, Langosch JM, Gerschlager W, Rothwell JC, Orth M, Trimble MR. Mirtazapine increases cortical excitability in healthy controls and epilepsy patients with major depression. Journal of Neurology, Neurosurgery & Psychiatry. Apr. 2005;76(4):527-33.
145 Murray G, Michalak EE, Axler A, Yaxley D, Hayashi B, Westrin A, et al. Relief of Chronic or Resistant Depression (ReChORD): A pragmatic, randomized, open-treatment trial of an integrative program intervention for chronic depression. Journal of Affective Disorders. June. 2010;123(1-3):243-8. [pmid: 19896200].
146 Nahas Z, DeBrux C, Chandler V, Lorberbaum JP, Speer AM, Molloy MA, et al. Lack of significant changes on magnetic resonance scans before and after 2 weeks of daily left prefrontal repetitive transcranial magnetic stimulation for depression. J Ect. Dec. 2000;16(4):380-90. [pmid: 11314876].
147 Nahas Z, Kozel FA, Li X, Anderson B, George MS. Left prefrontal transcranial magnetic stimulation (TMS) treatment of depression in bipolar affective disorder: a pilot study of acute safety and efficacy. Bipolar Disord. Feb. 2003;5(1):40-7. [pmid: 12656937].
148 Nahas Z, Teneback CC, Kozel A, Speer AM, DeBrux C, Molloy M, et al. Brain effects of TMS delivered over prefrontal cortex in depressed adults: Role of stimulation frequency and coil-cortex distance. Journal of Neuropsychiatry & Clinical Neurosciences. Fal. 2001;13(4):459-70. [pmid: 11748315].
149 Navarro V, Gasto C, Lomena F, Mateos JJ, Portella MJ, Masana G, et al. No brain perfusion impairment at long-term follow-up in elderly patients treated with electroconvulsive therapy for major depression. J Ect. Jun. 2004;20(2):89-93. [pmid: 15167424].
150 Navarro V, Gasto C, Torres X, Masana G, Penades R, Guarch J, et al. Continuation/maintenance treatment with nortriptyline versus combined nortriptyline and ECT in late-life psychotic depression: a two-year randomized study. Am J Geriatr Psychiatry. Jun. 2008;16(6):498-505. [pmid: 18515694].
151 Nelson JC, Mazure CM, Jatlow PI, Bowers MB Jr, Price LH. Combining norepinephrine and serotonin reuptake inhibition mechanisms for treatment of depression: a double-blind, randomized study. Biol Psychiatry. Feb. 1. 2004;55(3):296-300. [pmid: 14744472].
152 Nelson JC, Papakostas GI. Atypical antipsychotic augmentation in major depressive disorder: a meta-analysis of placebo-controlled randomized trials (Structured abstract). American Journal of Psychiatry. 2009:980-91.
153 Nemeroff CB, Heim CM, Thase ME, Klein DN, Rush AJ, Schatzberg AF, et al. Differential responses to psychotherapy versus pharmacotherapy in patients with chronic forms of major depression and childhood trauma. Proc Natl Acad Sci U S A. 2003/11/15. 2003:14293-6.
154 Nierenberg AA, Trivedi MH, Gaynes BN, Mitchell J, Davis LL, Husain MM, et al. Effectiveness study of venlafaxine-XR combined with aripiprazole for chronic or recurrent major depressive disorder. Australian and New Zealand Journal of Psychiatry. 2009;43(10):956-67.
155 O'Connor MG, Jerskey BA, Robertson EM, Brenninkmeyer C, Ozdemir E, Leone AP. The effects of repetitive transcranial magnetic stimulation (rTMS) on procedural memory and dysphoric mood in patients with major depressive disorder. Cogn Behav Neurol. Dec. 2005;18(4):223-7. [pmid: 16340396].
156 Padberg F, Zwanzger P, Keck ME, Kathmann N, Mikhaiel P, Ella R, et al. Repetitive transcranial magnetic stimulation (rTMS) in major depression: relation between efficacy and stimulation intensity. Neuropsychopharmacology. Oct. 2002;27(4):638-45. [pmid: 12377400].
157 Paillere Martinot ML, Galinowski A, Ringuenet D, Gallarda T, Lefaucheur JP, Bellivier F, et al. Influence of prefrontal target region on the efficacy of repetitive transcranial magnetic stimulation in patients with medication-resistant depression: A [18F]-fluorodeoxyglucose PET and MRI study. International Journal of Neuropsychopharmacology. 2010:45-59.
158 Pal E, Nagy F, Aschermann Z, Balazs E, Kovacs N. The impact of left prefrontal repetitive transcranial magnetic stimulation on depression in Parkinson's disease: A randomized, double-blind, placebo-controlled study. Movement Disorders. October. 2010;25(14):2311-7. [pmid: 20740485].
159 Papakostas GI, Fava M, Thase ME. Treatment of SSRI-resistant depression: a meta-analysis comparing within- versus across-class switches. Biol Psychiatry. Apr. 1. 2008;63(7):699-704. [pmid: 17919460].
160 Papakostas GI, Shelton RC, Smith J, Fava M. Augmentation of antidepressants with atypical antipsychotic medications for treatment-resistant major depressive disorder: a meta-analysis. J Clin Psychiatry. Jun. 2007;68(6):826-31. [pmid: 17592905].
161 Pardo JV, Sheikh SA, Schwindt GC, Lee JT, Kuskowski MA, Surerus C, et al. Chronic vagus nerve stimulation for treatment-resistant depression decreases resting ventromedial prefrontal glucose metabolism. Neuroimage. Aug. 15. 2008;42(2):879-89. [pmid: 18595737].
162 Parker G, Roy K, Hadzi-Pavlovic D, Pedic F. Psychotic (delusional) depression: A meta-analysis of physical treatments. Journal of Affective Disorders. 1992;24(1):17-24. [pmid: 1347545].
163 Parker G, Roy K, Wilhelm K, Mitchell P. Assessing the comparative effectiveness of antidepressant therapies: a prospective clinical practice study. J Clin Psychiatry. Feb. 2001;62(2):117-25. [pmid: 11247097].
164 Patkar AA, Masand PS, Pae CU, Peindl K, Hooper-Wood C, Mannelli P, et al. A Randomized, Double-blind, Placebo-controlled Trial of Augmentation with an Extended Release Formulation of Methylphenidate in Outpatients with Treatment-Resistant Depression. Journal of Clinical Psychopharmacology. 12. 2006;26(6):653-6. [pmid: 17110825].
165 Paul SM, Extein I, Calil HM. Use of ECT with treatment-resistant depressed patients at the National Institute of Mental Health. American Journal of Psychiatry. 1981;138(4):486-9. [pmid: 6111228].
166 Perry PJ, Morgan DE, Smith RE, Tsuang MT. Treatment of unipolar depression accompanied by delusions. ECT versus tricyclic antidepressant--antipsychotic combinations. J Affect Disord. Sep. 1982;4(3):195-200. [pmid: 6127358].
167 Peselow ED, Filippi AM, Goodnick P, Barouche F, Fieve RR. The short- and long-term efficacy of paroxetine HCl: B. Data from a double-blind crossover study and from a year-long term trial vs. imipramine and placebo. Psychopharmacol Bull. 1989/02/01. 1989:272-6.
168 Peselow ED, Filippi AM, Goodnick P, Barouche F, Fieve RR. The short- and long-term efficacy of paroxetine HCl: A. Data from a 6-week double-blind parallel design trial vs. imipramine and placebo. Psychopharmacol Bull. 1989;25(2):267-71. [pmid: 2532373].
169 Peterson TJ, Feldman G, Harley R, Fresco DM, Graves L, Holmes A, et al. Extreme response style in recurrent and chronically depressed patients: Change with antidepressant administration and stability during continuation treatment. Journal of Consulting and Clinical Psychology. Feb. 2007;75(1):145-53. [pmid: 17295573].
170 Philibert RA, Richards L, Lynch CF, Winokur G. Effect of ECT on mortality and clinical outcome in geriatric unipolar depression. Journal of Clinical Psychiatry. 1995;56(7 SUPPL.):390-4. [pmid: 7665536].
171 Pogarell O, Koch W, Pöpperl G, Tatsch K, Jakob F, Zwanzger P, et al. Striatal dopamine release after prefrontal repetitive transcranial magnetic stimulation in major depression: preliminary results of a dynamic [123I] IBZM SPECT study. Journal of Psychiatric Research. Jun. 2006;40(4):307-14. [pmid: 16259998].
172 Poulet E, Brunelin J, Boeuve C, Lerond J, D'Amato T, Dalery J, et al. Repetitive transcranial magnetic stimulation does not potentiate antidepressant treatment. Eur Psychiatry. Sep. 2004;19(6):382-3. [pmid: 15363481].
173 Pridmore S, Bruno R, Turnier-Shea Y, Reid P, Rybak M. Comparison of unlimited numbers of rapid transcranial magnetic stimulation (rTMS) and ECT treatment sessions in major depressive episode. International Journal of Neuropsychopharmacology. Jun. 2000;3(2):129-34. [pmid: 11343589].
174 Prudic J, Sackeim HA, Devanand DP. Medication resistance and clinical response to electroconvulsive therapy. Psychiatry Research. 1990;31(3):287-96. [pmid: 1970656].
175 Quilty LC, De Fruyt F, Rolland JP, Kennedy SH, Rouillon PF, Bagby RM. Dimensional personality traits and treatment outcome in patients with major depressive disorder. J Affect Disord. Jun. 2008;108(3):241-50. [pmid: 18067975].
176 Rami L, Goti J, Ferrer J, Marcos T, Salamero M, Bernardo M. Cognitive functions after only one ECT session: a controlled study. Psychiatry Res. Apr. 15. 2008;158(3):389-94. [pmid: 18279973].
177 Rasmussen KG, Knapp RG, Biggs MM, Smith GE, Rummans TA, Petrides G, et al. Data management and design issues in an unmasked randomized trial of electroconvulsive therapy for relapse prevention of severe depression: the consortium for research in electroconvulsive therapy trial. J Ect. Dec. 2007;23(4):244-50. [pmid: 18090697].
178 Reimherr F, Amsterdam J, Dunner D, Adler L, Zhang S, Williams D, et al. Genetic polymorphisms in the treatment of depression: speculations from an augmentation study using atomoxetine. Psychiatry Res. Jan. 30. 2010;175(1-2):67-73. [pmid: 19969374].
179 Reynolds CF III, Frank E, Houck PR, Mazumdar S, Dew MA, Cornes C, et al. Which elderly patients with remitted depression remain well with continued interpersonal psychotherapy after discontinuation of antidepressant medication?. American Journal of Psychiatry. 1997;154(7):958-62. [pmid: 9210746].
180 Reynolds CF III, Frank E, Kupfer DJ, Thase ME, Perel JM, Mazumdar S, et al. Treatment outcome in recurrent major depression: A post hoc comparison of elderly ('young old') and midlife patients. American Journal of Psychiatry. 1996;153(10):1288-92. [pmid: 8831436].
181 Reynolds CF III, Miller MD, Pasternak RE, Frank E, Perel JM, Cornes C, et al. Treatment of bereavement-related major depressive episodes in later life: A controlled study of acute and continuation treatment with nortriptyline and interpersonal psychotherapy. American Journal of Psychiatry. 1999;156(2):202-8. [pmid: 9989555].
182 Reynolds CF I, Frank E, Perel JM, Imber SD, Cornes C, Miller MD, et al. Nortriptyline and interpersonal psychotherapy as maintenance therapies for recurrent major depression. A randomized controlled trial in patients older than 59 years. Journal of the American Medical Association. 1999;281(1):39-45. [pmid: 9892449].
183 Reynolds CF I, Frank E, Perel JM, Miller MD, Cornes C, Rifai AH, et al. Treatment of consecutive episodes of major depression in the elderly. American Journal of Psychiatry. 1994;151(12):1740-3. [pmid: 7977879].
184 Rodriguez-Martin José L, Barbanoj José M, Schlaepfer TE, Clos Susana SC, Pérez V, Kulisevsky J, et al. Transcranial magnetic stimulation for treating depression, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2001.
185 Rollnik JD, Huber TJ, Mogk H, Siggelkow S, Kropp S, Dengler R, et al. High frequency repetitive transcranial magnetic stimulation (rTMS) of the dorsolateral prefrontal cortex in schizophrenic patients. Neuroreport: For Rapid Communication of Neuroscience Research. Dec. 2000;11(18):4013-5.
186 Rossini D, Lucca A, Zanardi R, Magri L, Smeraldi E. Transcranial magnetic stimulation in treatment-resistant depressed patients: a double-blind, placebo-controlled trial. Psychiatry Res. Nov. 15. 2005;137(1-2):1-10. [pmid: 16225930].
187 Rothschild AJ, Williamson DJ, Tohen MF, Schatzberg A, Andersen SW, Van Campen LE, et al. A double-blind, randomized study of olanzapine and olanzapine/fluoxetine combination for major depression with psychotic features. J Clin Psychopharmacol. Aug. 2004;24(4):365-73. [pmid: 15232326].
188 Rubin EH, Kinscherf DA, Figiel GS, Zorumski CF. The nature and time course of cognitive side effects during electroconvulsive therapy in the elderly. J Geriatr Psychiatry Neurol. Apr-Jun. 1993;6(2):78-83. [pmid: 8512634].
189 Ruhe HG, Huyser J, Swinkels JA, Schene AH. Switching antidepressants after a first selective serotonin reuptake inhibitor in major depressive disorder: a systematic review. J Clin Psychiatry. Dec. 2006;67(12):1836-55. [pmid: 17194261].
190 Rumi DO, Gattaz WF, Rigonatti SP, Rosa MA, Fregni F, Rosa MO, et al. Transcranial magnetic stimulation accelerates the antidepressant effect of amitriptyline in severe depression: a double-blind placebo-controlled study. Biol Psychiatry. Jan. 15. 2005;57(2):162-6. [pmid: 15652875].
191 Rush AJ, George MS, Sackeim HA, Marangell LB, Husain MM, Giller C, et al. Vagus nerve stimulation (VNS) for treatment-resistant depressions: a multicenter study. Biological Psychiatry. 2000;47(4):276-86. [pmid: 10686262].
192 Rush AJ, Trivedi MH, Wisniewski SR, Stewart JW, Nierenberg AA, Thase ME, et al. Bupropion-SR, sertraline, or venlafaxine-XR after failure of SSRIs for depression. N Engl J Med. Mar. 23. 2006;354(12):1231-42. [pmid: 16554525].
193 Sackeim HA, Haskett RF, Mulsant BH, Thase ME, Mann JJ, Pettinati HM, et al. Continuation pharmacotherapy in the prevention of relapse following electroconvulsive therapy: a randomized controlled trial. Jama. Mar. 14. 2001;285(10):1299-307. [pmid: 11255384].
194 Salinsky MC. A randomized controlled trial of chronic vagus nerve stimulation for treatment of medically intractable seizures. Neurology. 1995;45(2):224-30. [pmid: 7854516].
195 Schat A, van den Broek WW, Mulder PG, Birkenhager TK, van Tuijl R, Murre JM. Changes in everyday and semantic memory function after electroconvulsive therapy for unipolar depression. J Ect. Sep. 2007;23(3):153-7. [pmid: 17804988].
196 Schatzberg AF, Rush AJ, Arnow BA, Banks PL, Blalock JA, Borian FE, et al. Chronic depression: medication (nefazodone) or psychotherapy (CBASP) is effective when the other is not. Arch Gen Psychiatry. May. 2005;62(5):513-20. [pmid: 15867104].
197 Schneider LS, Sloane RB, Staples FR, Bender M. Pretreatment orthostatic hypotension as a predictor of response to nortriptyline in geriatric depression. Journal of Clinical Psychopharmacology. 1986;6(3):172-6. [pmid: 3711368].
198 Schopf J, Baumann P, Lemarchand T, Rey M. Treatment of endogenous depressions resistant to tricyclic antidepressants or related drugs by lithium addition. Results of a placebo-controlled double-blind study. Pharmacopsychiatry. Sep. 1989;22(5):183-7. [pmid: 2682692].
199 Schuster P, Opgenoorth E, Gabriel E, Presslich O, Sowinetz B. Results of learning experiments in the course of treatment of endogenomorphic depression. A comparison of electroconvulsive and pharmacological treatment. Psychopathology. 1986;19(3):116-30. [pmid: 3737823].
200 Schutter DJ. Antidepressant efficacy of high-frequency transcranial magnetic stimulation over the left dorsolateral prefrontal cortex in double-blind sham-controlled designs: a meta-analysis. Psychol Med. Jan. 2009;39(1):65-75. [pmid: 18447962].
201 Schutter DJLG, Martin Laman D, Van Honk J, Vergouwen AC, Frank Koerselman G. Partial clinical response to 2 weeks of 2 Hz repetitive transcranial magnetic stimulation to the right parietal cortex in depression. International Journal of Neuropsychopharmacology. June. 2009;12(5):643-50. [pmid: 18925985].
202 Schutter DJLG, van Honk J, Laman M, Vergouwen AC, Koerselman F. Increased sensitivity for angry faces in depressive disorder following 2 weeks of 2-Hz repetitive transcranial magnetic stimulation to the right parietal cortex. International Journal of Neuropsychopharmacology. 2010;13(9):1155-61. [pmid: 20587129].
203 Scott AIF, Freeman CPL. Edinburgh primary care depression study: Treatment outcome, patient satisfaction, and cost after 16 weeks. British Medical Journal. 1992;304(6831):883-7. [pmid: 1392754].
204 Shapira B, Gorfine M, Lerer B. A prospective study of lithium continuation therapy in depressed patients who have responded to electroconvulsive therapy. Convuls Ther. Jun. 1995;11(2):80-5. [pmid: 7552058].
205 Shiah IS, Yatham LN, Srisurapanont M, Lam RW, Tam EM, Zis AP. Does the addition of pindolol accelerate the response to electroconvulsive therapy in patients with major depression? A double-blind, placebo-controlled pilot study. J Clin Psychopharmacol. Jun. 2000;20(3):373-8. [pmid: 10831027].
206 Smith GE, Rasmussen KG Jr, Cullum CM, Felmlee-Devine MD, Petrides G, Rummans TA, et al. A randomized controlled trial comparing the memory effects of continuation electroconvulsive therapy versus continuation pharmacotherapy: results from the Consortium for Research in ECT (CORE) study. J Clin Psychiatry. Feb. 2010;71(2):185-93. [pmid: 20193646].
207 Sneed JR, Roose SP, Keilp JG, Krishnan KR, Alexopoulos GS, Sackeim HA. Response inhibition predicts poor antidepressant treatment response in very old depressed patients. Am J Geriatr Psychiatry. Jul. 2007;15(7):553-63. [pmid: 17586780].
208 Souza FG, Goodwin GM. Lithium treatment and prophylaxis in unipolar depression: a meta-analysis. Br J Psychiatry. May. 1991;158:666-75. [pmid: 1830506].
209 Spalletta G, Guida G, Caltagirone C. Is left stroke a risk-factor for selective serotonin reuptake inhibitor antidepressant treatment resistance?. J Neurol. Apr. 2003;250(4):449-55. [pmid: 12700911].
210 Speer AM, Repella JD, Figueras S, Demian NK, Kimbrell TA, Wasserman EM, et al. Lack of adverse cognitive effects of 1 Hz and 20 Hz repetitive transcranial magnetic stimulation at 100% of motor threshold over left prefrontal cortex in depression. J Ect. Dec. 2001;17(4):259-63. [pmid: 11731727].
211 Squire LR, Slater PC. Electroconvulsive therapy and complaints of memory dysfunction: a prospective three-year follow-up study. Br J Psychiatry. Jan. 1983;142:1-8. [pmid: 6831121].
212 Stain-Malmgren R, Khoury AE, Aberg-Wistedt A, Tham A. Serotonergic function in major depression and effect of sertraline and paroxetine treatment. Int Clin Psychopharmacol. Mar. 2001;16(2):93-101. [pmid: 11236074].
213 Stein G, Bernadt M. Lithium augmentation therapy in tricyclic-resistant depression. A controlled trial using lithium in low and normal doses. Br J Psychiatry. May. 1993;162:634-40. [pmid: 8149115].
214 Stek ML, Van der Wurff FB, Hoogendijk WL, Beekman AT. Electroconvulsive therapy for the depressed elderly. Cochrane Database Syst Rev. 2003;(2). CD003593.
215 Stern WC, Harto-Truax N, Bauer N. Efficacy of bupropion in tricyclic-resistant or intolerant patients. J Clin Psychiatry. May. 1983;44(5 Pt 2):148-52. [pmid: 6406447].
216 Stewart JW, McGrath PJ, Quitkin FM. Do age of onset and course of illness predict different treatment outcome among DSM IV depressive disorders with atypical features?. Neuropsychopharmacology. Feb. 2002;26(2):237-45. [pmid: 11790519].
217 Stiebel VG. Maintenance electroconvulsive therapy for chronic mentally ill patients: a case series. Psychiatr Serv. Mar. 1995;46(3):265-8. [pmid: 7796215].
218 Stoudemire A, Hill CD, Morris R, Martino-Saltzman D, Lewison B. Long-term affective and cognitive outcome in depressed older adults. Am J Psychiatry. Jun. 1993;150(6):896-900. [pmid: 8494065].
219 Swartz CM, Morrow V, Surles L, James JF. Long-term outcome after ECT for catatonic depression. J Ect. Sep. 2001;17(3):180-3. [pmid: 11528308].
220 Swoboda E, Conca A, Konig P, Waanders R, Hansen M. Maintenance electroconvulsive therapy in affective and schizoaffective disorder. Neuropsychobiology. Jan. 2001;43(1):23-8. [pmid: 11150895].
221 Szuba MP, O'Reardon JP, Rai AS, Snyder-Kastenberg J, Amsterdam JD, Gettes DR, et al. Acute mood and thyroid stimulating hormone effects of transcranial magnetic stimulation in major depression. Biol Psychiatry. Jul. 1. 2001;50(1):22-7. [pmid: 11457420].
222 Taylor MP, Reynolds Iii CE, Frank E, Cornes C, Miller MD, Stack JA, et al. Which elderly depressed patients remain well on maintenance interpersonal psychotherapy alone?: Report from the Pittsburgh Study of Maintenance Therapies in late-life depression. Depression and Anxiety. 1999;10(2):55-60. [pmid: 10569127].
223 Tew JD Jr, Mulsant BH, Houck PR, Lenze EJ, Whyte EM, Miller MD, et al. Impact of prior treatment exposure on response to antidepressant treatment in late life. Am J Geriatr Psychiatry. Nov. 2006;14(11):957-65. [pmid: 17068318].
224 Thase ME, Rush AJ, Howland RH, Kornstein SG, Kocsis JH, Gelenberg AJ, et al. Double-blind switch study of imipramine or sertraline treatment of antidepressant-resistant chronic depression. Arch Gen Psychiatry. Mar. 2002;59(3):233-9. [pmid: 11879161].
225 Thase ME, Shelton RC, Khan A. Treatment with venlafaxine extended release after SSRI nonresponse or intolerance: a randomized comparison of standard- and higher-dosing strategies. J Clin Psychopharmacol. Jun. 2006;26(3):250-8. [pmid: 16702889].
226 Thomas SA, Lincoln NB. Factors relating to depression after stroke. British Journal of Clinical Psychology. 2006;45(1):49-61. [pmid: 16480566].
227 Thompson C, Thompson CM. Treatment resistant or irresolutely treated. Int Clin Psychopharmacol. Jul. 1. 1991;6:31-8. discussion 8-9. [pmid: 1757717].
228 Thompson LW, Gallagher D, Breckenridge JS. Comparative effectiveness of psychotherapies for depressed elders. Journal of Consulting and Clinical Psychology. 1987;55(3):385-90. [pmid: 3597953].
229 Tielkes CE, Comijs HC, Verwijk E, Stek ML. The effects of ECT on cognitive functioning in the elderly: a review. Int J Geriatr Psychiatry. Aug. 2008;23(8):789-95. [pmid: 18311845].
230 Trivedi MH, Fava M, Wisniewski SR, Thase ME, Quitkin F, Warden D, et al. Medication augmentation after the failure of SSRIs for depression. N Engl J Med. Mar. 23. 2006;354(12):1243-52. [pmid: 16554526].
231 Tsourtos G, Spong J, Stough C. The effects of electro-convulsive therapy on the speed of information processing in major depression. J Affect Disord. Nov. 2007;103(1-3):263-6. [pmid: 17328957].
232 van den Broek WW, Birkenhager TK, Mulder PG, Bruijn JA, Moleman P. Imipramine is effective in preventing relapse in electroconvulsive therapy-responsive depressed inpatients with prior pharmacotherapy treatment failure: a randomized, placebo-controlled trial. J Clin Psychiatry. Feb. 2006;67(2):263-8. [pmid: 16566622].
233 Van Der Starre PJA, Lemmens HJM, Chandel A, Solvason HB, Brock-Utne JG. The effects of esmolol and labetalol on cerebral blood flow velocity during electroconvulsive therapy [6]. European Journal of Anaesthesiology. 2008;25(2):174-6. [pmid: 18251042].
234 Van Der Wurff FB, Stek ML, Hoogendijk WJ, Beekman AT. The efficacy and safety of ECT in depressed older adults: a literature review (Brief record). International Journal of Geriatric Psychiatry. 2003;(10):894-904. [pmid: 14533122].
235 Van Schaik A, Van Marwijk H, Adèr H, Van Dyck R, De Haan M, Penninx B, et al. Interpersonal psychotherapy for elderly patients in primary care. American Journal of Geriatric Psychiatry. 2006;14(9):777-86. [pmid: 16943174].
236 Vanderhasselt MA, De Raedt R, Baeken C, Leyman L, D'Haenen H. A single session of rTMS over the left dorsolateral prefrontal cortex influences attentional control in depressed patients. World J Biol Psychiatry. 2009;10(1):34-42. [pmid: 19673086].
237 Vothknecht S, Kho KH, van Schaick HW, Zwinderman AH, Middelkoop H, Blansjaar BA. Effects of maintenance electroconvulsive therapy on cognitive functions. J Ect. Sep. 2003;19(3):151-7. [pmid: 12972985].
238 Wesson ML, Wilkinson AM, Anderson DN, Cracken CM. Does age predict the long-term outcome of depression treated with ECT? (a prospective study of the long-term outcome of ECT-treated depression with respect to age). Int J Geriatr Psychiatry. Jan. 1997;12(1):45-51. [pmid: 9050423].
239 White K, Wykoff W, Tynes LL, Schneider L, Zemansky M. Fluvoxamine in the treatment of tricyclic-resistant depression. Psychiatr J Univ Ott. Sep. 1990;15(3):156-8. [pmid: 2123039].
240 Wijkstra J, Burger H, van den Broek WW, Birkenhager TK, Janzing JG, Boks MP, et al. Treatment of unipolar psychotic depression: a randomized, double-blind study comparing imipramine, venlafaxine, and venlafaxine plus quetiapine. Acta Psychiatr Scand. 2009/08/22. 2010:190-200.
241 Wijkstra J, Lijmer J, Balk F, Geddes J, Nolen Willem A. Pharmacological treatment for psychotic depression, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2005.
242 Williams N, Simpson AN, Simpson K, Nahas Z. Relapse rates with long-term antidepressant drug therapy: a meta-analysis. Hum Psychopharmacol. 2009/06/16. 2009:401-8.
243 Wilson K, Mottram PG, Vassilas C. Psychotherapeutic treatments for older depressed people. Cochrane Database of Systematic Reviews. 2008;(1).
244 Winokur G, Coryell W, Keller M, Scheftner WA. Relationship of electroconvulsive therapy to course in affective illness: a collaborative study. Eur Arch Psychiatry Clin Neurosci. 1990;240(1):54-9. [pmid: 2147905].
245 Zapletalek M, Zbytovsky J, Kudrnova K. Clinical experience with maprotilin and maprotilin/clomipramine infusions in resistant depression. Act Nerv Super (Praha). May. 1982;24(2):73-6. [pmid: 7102227].
246 Ziemann U, Iliac TV, Pauli C, Meintzschel F, Ruge D. Learning modifies subsequent induction of long-term potentiation-like and long-term depression-like plasticity in human motor cortex. Journal of Neuroscience. Feb. 2004;24(7):1666-72. [pmid: 14973238].
247 Zisook S, Rush AJ, Haight BR, Clines DC, Rockett CB. Use of bupropion in combination with serotonin reuptake inhibitors. Biol Psychiatry. Feb. 1. 2006;59(3):203-10. [pmid: 16165100].
248 Zusky PM, Biederman J, Rosenbaum JF, Manschreck TC, Gross CC, Weilberg JB, et al. Adjunct low dose lithium carbonate in treatment-resistant depression: a placebo-controlled study. J Clin Psychopharmacol. Apr. 1988;8(2):120-4. [pmid: 3131389].
249 Zvara DA, Brooker RF, McCall WV, Foreman AS, Hewitt C, Murphy BA, et al. The effect of esmolol on ST-segment depression and arrhythmias after electroconvulsive therapy. Convuls Ther. Sep. 1997;13(3):165-74. [pmid: 9342132].

## Wrong Publication Type

1 Vagus nerve stimulation for treatment-resistance depression. Technol Eval Cent Asses Program Exec Summ. Aug. 2005;20(8):1-2.
2 Transcranial magnetic stimulation for depression. Technol Eval Cent Asses Program Exec Summ. Oct. 2009;24(5):1-3.
3 Easing the burden of treatment-resistant depression. J Clin Psychiatry. Feb. 2009;70(2):273-80. [pmid: 19265643].
4 Options for treatment-resistant depression. Why electroconvulsive therapy may be the best alternative to medication. Harv Ment Health Lett. Jan. 2009;25(7):1-3.
5 ranscranial magnetic stimulation. Research helps clarify who is likely to benefit from this treatment. Harv Ment Health Lett. Sep. 2010;27(3):6.
6 Abramowitz MZ, Lichtenberg P, Marcus EL, Shapira B. Treating a Holocaust survivor without addressing the Holocaust: a case report. Clinical Gerontologist. 1994;14(3):75-80.
7 Abrams R. Is unilateral electroconvulsive therapy really the treatment of choice in endogenous depression?. Ann N Y Acad Sci. 1986;462:50-5. [pmid: 3518574].
8 American Psychiatric Association. Committee on Electroconvulsive T, Weiner RD. The practice of electroconvulsive therapy : a task force report of the american Psychiatric Association. Washington, D.C. American Psychiatric Assoication.
9 Asaknow JR, Emslie G, Clarke G, Wagner KD, Spirito A, Vitiello B, et al. Treatment of selective serotonin reuptake inhibitor-resistant depression in adolescents: predictors and moderators of treatment response. J Am Acad Child Adolesc Psychiatry. 2009;48(3):330-9. [pmid: 19182688].
10 Ashton AK. Depressive relapse after vagal nerve stimulator explantation. Am J Psychiatry. Jun. 2010;167(6):719-20. [pmid: 20516167].
11 Avery D. Transcranial magnetic stimulation in the treatment of depression. Essent Psychopharmacol. 2001;4:37-48.
12 Bachar E, Lerer B, Shapira B. Increment in reminiscing after ECT: possible connections to neuropsychologic changes [2]. J ECT. 1999;15(2):165-6. [pmid: 10378158].
13 Barker AT, Jalinous R, Freeston H, Jarratt JA. Motor responses to noninvasive brain stimulation in clinical practice. Electroencephalogr Clin Neurophysiol. 1985;61:570-4.
14 Barker AT, Jalinous R, Freeston IL. Noninvasive magnetic stimulation of human motor cortex. Lancet. 1985;1(8437):1106-7. [pmid: 2860322].
15 Bauer M, Adli M, Bschor T, Pilhatsch M, Pfennig A, Sasse J, et al. Lithium's emerging role in the treatment of refractory major depressive episodes: augmentation of antidepressants. Neuropsychobiology. 2010/05/11. 2010:36-42.
16 Bech P, Stokes PE, Greden JF, Tollefson GD. Acute therapy of depression. Journal of Clinical Psychiatry. 1993;54(8 SUPPL):18-27. [pmid: 8253702].
17 Bobo WV, Shelton RC. Fluoxetine and olanzapine combination therapy in treatment-resistant major depression: review of efficacy and safety data. Expert Opin Pharmacother. Sep. 2009;10(13):2145-59. [pmid: 19640209].
18 Bobo WV, Shelton RC. Efficacy, safety and tolerability of Symbyax for acute-phase management of treatment-resistant depression. Expert Rev Neurother. May. 2010;10(5):651-70. [pmid: 20420487].
19 Borckardt JJ, Anderson B, Kozel FA, Nahas Z, Smith AR, Thomas KJ, et al. Acute and long-term VNS effects on pain perception in a case of treatment-resistant depression. Neurocase. Aug. 2006;12(4):216-20. [pmid: 17000590].
20 Chaput Y, Magnan A, Gendron A. The coadministration of quetiapine or placebo to cognitive-behavior therapy in treatment refractory depression: a preliminary trial. BMC Psychiatry. 2008;8:73. [pmid: 18752690].
21 Cheema FA, Badr A, Iqbal J. Glioblastoma multiforme presenting as treatment-resistant depression. Journal of Neuropsychiatry and Clinical Neurosciences. Winter. 2010;22(1):E26. [pmid: 20160235].
22 Christmas David MB, Crombie I, Eljamel S, Fineberg N, MacVicar B, Matthews K, et al. Neurosurgery for obsessive-compulsive disorder, other anxiety disorders and depressive disorders, Cochrane Database of Systematic Reviews. Chichester, UK. John Wiley & Sons, Ltd. 2005.
23 Conca A, König P, Hausmann A. Transcranial magnetic stimulation induces 'pseudoabsence seizure '. Acta Psychiatrica Scandinavica. Mar. 2000;101(3):246-8. [pmid: 10721875].
24 Coryell W, Tsuang MT. Primary unipolar depression and the prognostic importance of delusions. Arch Gen Psychiatry. Oct. 1982;39(10):1181-4. [pmid: 7125847].
25 Crow TJ, Johnstone EC. Controlled trials of electroconvulsive therapy. Ann N Y Acad Sci. 1986;462:12-29. [pmid: 2871792].
26 Croxtall JD, Scott LJ. Olanzapine/fluoxetine: a review of its use in patients with treatment-resistant major depressive disorder. CNS Drugs. Mar. 1. 2010;24(3):245-62. [pmid: 20155998].
27 Culpepper L. Why do you need to move beyond first-line therapy for major depression?. J Clin Psychiatry. 2010/11/05. 2010:4-9.
28 Demitrack MA, Thase ME. Clinical significance of transcranial magnetic stimulation (TMS) in the treatment of pharmacoresistant depression: synthesis of recent data. Psychopharmacol Bull. 2009/07/25. 2009:5-38.
29 Dinan TG. A rational approach to the nonresponding depressed patient. International Clinical Psychopharmacology. 1993;8(4):221-3. [pmid: 8277139].
30 Dunner DL, Russell JM. A long-term, naturalistic study of usual standard-of-care treatment in patients with treatment resistant depression. Proceedings of the ACNP Annual Meeting. San Juan, Puerto Rico. December 2003. 2003:150.
31 Ella R, Zwanzger P, Stampfer R, Preuss UW, Müller-Siecheneder F, Möller HJ, et al. Switch to mania after slow rTMS of the right prefrontal cortex. Journal of Clinical Psychiatry. Mar. 2002;63(3):249. [pmid: 11926727].
32 Fava M. The combination of buspirone and bupropion in the treatment of depression. Psychother Psychosom. 2007;76(5):311-2. [pmid: 17700052].
33 Fink M. Electroshock: restoring the mind. New York. Oxford University Press. 1999.
34 Fink M. Electroconvulsive therapy in medication-resistant depression. Treatment-Resistant Mood Disorders. 2001:223-38.
35 Floyd MR. Cognitive therapy for depression: a comparison of individual psychotherapy and bibliotherapy for depressed older adults. Dissertation Abstracts International. 1999;58(9 -B):5081.
36 Gaynes BN, Rush AJ, Trivedi MH, Wisniewski SR, Spencer D, Fava M. The STAR*D study: treating depression in the real world. Cleve Clin J Med. Jan. 2008;75(1):57-66. [pmid: 18236731].
37 Geddes J, Butler R. Depressive disorders. Clin Evid. Jun. 2002;(7):867-82. [pmid: 12230711].
38 George MS, Belmaker RH. Transcranial magnetic stimulation in neuropsychiatry. Washington, DC. American Psychiatric Press. 2000.
39 George MS, Sackeim HA, Marangell LB, Husain MM, Nahas Z, Lisanby SH, et al. Vagus nerve stimulation: A potential therapy for resistant depression?. Psychiatric Clinics of North America. Dec. 2000;23(4):757-83. [pmid: 11147246].
40 George MS, Wassermann EM. Rapid-rate transcranial magnetic stimulation and ECT. Convulsive Therapy. 1994;10(4):251-4. discussion 5. [pmid: 7850394].
41 Gershon AA, Dannon PN, Grunhaus L. Transcranial magnetic stimulation in the treatment of depression. Am J Psychiatry. May. 2003;160(5):835-45. [pmid: 12727683].
42 Goff DC, Jenike MA. Treatment-resistant depression in the elderly. J Am Geriatr Soc. Jan. 1986;34(1):63-70. [pmid: 3510242].
43 Goforth HW, Carroll BT. Aripiprazole augmentation of tranylcypromine in treatment-resistant major depression [8]. Journal of Clinical Psychopharmacology. Apr. 2007;27(2):216-7. [pmid: 17414252].
44 Goodnick PJ, Barrios CA. Use of olanzapine in non-psychotic psychiatric disorders. Expert Opinion on Pharmacotherapy. 2001;2(4):667-80. [pmid: 11336615].
45 Gormley N. ECT should be treatment option in all cases of refractory depression [7]. British Medical Journal. 1998;316(7126):233. [pmid: 9468718].
46 Grisaru N, Yarovslavsky U, Abarbanel J, Lamberg T, Belmaker RH. Transcranial magnetic stimulation in depression and schizophrenia. European Neuropsychopharmacology. 1994;4(3):287-8.
47 Grunhaus L, Remen A. Assessment of treatment-resistant major depression - The Michigan adequacy of treatment scale [4]. Journal of Clinical Psychopharmacology. 1993;13(3):221-3. [pmid: 8354741].
48 Guthrie SK, Sung JCY, Goodson J, Grunhaus L, Tandon R. Triazolam and diphenhydramine effects on seizure duration in depressed patients receiving ECT. Convulsive Therapy. 1996;12(4):261-5. [pmid: 9034702].
49 Herwig U, Lampe Y, Juengling FD, Wunderlich A, Walter H, Spitzer M, et al. Add-on rTMS for treatment of depression: a pilot study using stereotaxic coil-navigation according to PET data. Journal of Psychiatric Research. Jul-Aug. 2003;37(4):267-75. [pmid: 12765849].
50 Höflich G, Kasper S, Hufnagel A, Ruhrmann S, Möller HJ. Application of transcranial magnetic stimulation in treatment of drug-resistant major depression: A report of two cases. Human Psychopharmacology: Clinical and Experimental. Sep-Oct. 1993;8(5):361-5.
51 Hoflich G, Kasper S, Hufnagel A, Ruhrmann S, Moller HJ. Application of transcranial magnetic stimulation in treatment of drug-resistant major depression - A report of two cases. Human Psychopharmacology. 1993;8(5):361-5.
52 Holtzheimer PE, Avery D, Schlaepfer TE. Antidepressant effects of repetitive transcranial magnetic stimulation [4]. British Journal of Psychiatry. 2004;184(JUNE):541-2. [pmid: 15172952].
53 Howland RH. Chronic depression. Hospital and Community Psychiatry. 1993;44(7):633-9. [pmid: 8354502].
54 Huang CC, Su TP, Shan IK, Chang K, Wei IH. An open trial of daily left prefrontal cortex repetitive transcranial magnetic stimulation for treating medication-resistant depression. Eur Psychiatry. Dec. 2004;19(8):523-4. [pmid: 15589718].
55 Iosifescu DV, Bankier B, Fava M. Impact of medical comorbid disease on antidepressant treatment of major depressive disorder. Current Psychiatry Reports. 2004;6(3):193-201. [pmid: 15142472].
56 Johnson BA, Cowen PJ. Calcium channel blockade and resistant bipolar depression. Irish Journal of Psychological Medicine. Mar. 1991;8(1):50-1.
57 Jorge RE, Robinson RG, O'Brien J. Top cited papers in international psychogeriatrics: 5. A controlled study of repetitive transcranial magnetic stimulation as a treatment of depression in the elderly. Int Psychogeriatr. Oct. 2009;21(5):855-60. [pmid: 19589195].
58 Kaplan B, Chistyakov A, Kreinin I, Hafner H, Feinsod M, Klein E. The effect of electro-convulsive therapy and repetitive transcranial magnetic stimulation on cortical excitability in patients with major depression. Muscle & Nerve Supplement. 2003:12.
59 Kellner CH, Husain M, Petrides G, Fink M, Rummans T. Comment on “Repetitive transcranial magnetic stimulation versus electroconvulsive therapy for major depression: preliminary results of a randomized trial”. Biol Psychiatry. Nov. 15. 2002;52(10):1032-3. discussion 3. [pmid: 12437944].
60 Kellner M. Aripiprazole in a therapy-resistant patient with borderline personality and post-traumatic stress disorder. Pharmacopsychiatry. Jan. 2007;40(1):41. [pmid: 17327963].
61 Kiloh LG. Non-pharmacological biological treatments of psychiatric patients. Aust N Z J Psychiatry. Sep. 1983;17(3):215-25. [pmid: 6360121].
62 Kimball JN, Rosenquist PB, Dunn A, McCall V. Prediction of antidepressant response in both 2.25xthreshold RUL and fixed high dose RUL ECT. J Affect Disord. Jan. 2009;112(1-3):85-91. [pmid: 18539340].
63 Kojima H, Terao T, Yoshimura R. Serotonin syndrome during clomipramine and lithium treatment [1]. American Journal of Psychiatry. 1993;150(12).
64 Li X, Nahas Z, Anderson B, Kozel FA, George MS. Can left prefrontal rTMS be used as a maintenance treatment for bipolar depression?. Depression and Anxiety. 2004;20(2):98-100. [pmid: 15390210].
65 Loo CK, Kaill A, Paton P, Simpson B. The difficult-to-treat electroconvulsive therapy patient - Strategies for augmenting outcomes. Journal of affective disorders. August. 2010;124(3):219-27. [pmid: 19647325].
66 Loo CK, McFarquhar TF, Mitchell PB. A review of the safety of repetitive transcranial magnetic stimulation as a clinical treatment for depression. Int J Neuropsychopharmacol. Feb. 2008;11(1):131-47. [pmid: 17880752].
67 Loo CK, Mitchell PB. A review of the efficacy of transcranial magnetic stimulation (TMS) treatment for depression, and current and future strategies to optimize efficacy. J Affect Disord. Nov. 2005;88(3):255-67. [pmid: 16139895].
68 McNamara B, Ray JL, Arthurs OJ, Boniface S. Transcranial magnetic stimulation for depression and other psychiatric disorders. Psychological Medicine. 2001;31(7):1141-6. [pmid: 11681540].
69 Milev R, Abraham G, Hasey G, Cabaj JL. Repetitive transcranial magnetic stimulation for treatment of medication-resistant depression in older adults: a case series. J Ect. Mar. 2009;25(1):44-9. [pmid: 18665102].
70 Morgan PT. Treatment-resistant depression: Response to low-dose transdermal but not oral selegiline [10]. Journal of Clinical Psychopharmacology. Jun. 2007;27(3):313-4. [pmid: 17502787].
71 Moustgaard G. Treatment-refractory depression successfully treated with the combination of mirtazapine and lithium. J Clin Psychopharmacol. 2000:268.
72 Mulrow CD, Williams JW Jr, Trivedi M, Chiquette E, Aguilar C, Cornell JE, et al. Treatment of depression--newer pharmacotherapies. Psychopharmacol Bull. 1998;34(4):409-795. [pmid: 10513454].
73 Nierenberg AA, Katz J, Fava M. A critical overview of the pharmacologic management of treatment-resistant depression. Psychiatr Clin North Am. Mar. 2007;30(1):13-29. [pmid: 17362800].
74 Nolen WA, Van Den Broek WW, Birkenhager TK. Treatment with low doses of tranylcypromine resulted in a disappointing remission rate [1]. American Journal of Psychiatry. 2007;164(3):524. [pmid: 17329480].
75 Okamoto H, Shimizu E, Ozawa K, Hashimoto K, Iyo M. Lithium augmentation in milnacipran-refractory depression for the prevention of relapse following electroconvulsive therapy [1]. Australian and New Zealand Journal of Psychiatry. Jan. 2005;39(1-2):108. [pmid: 15660714].
76 Okay T, Sengul C, Gulunay A, Sengul CB, Erken DD, Dilbaz N. The short term effects of naproxen sodium on treatment satisfaction and headache as a side-effect of electroconvulsive therapy: A preliminary study. Klinik Psikofarmakoloji Bulteni. 2008;18(1):41-5.
77 Pascual-Leone A, Tormos JM, Keenan J, Tarazona F, CaÃ±ete C, CatalÃ¡ MD. Study and modulation of human cortical excitability with transcranial magnetic stimulation. Journal of Clinical Neurophysiology. 1998;15(4):333-43. [pmid: 9736467].
78 Poirier MF. [The concept of resistant depression and therapeutic strategies, particularly, with venlafaxine]. Encephale. Jun. 1999;25(Spec No 2):55-7. discussion 8-61. [pmid: 10434160].
79 Rasmussen KG. Electroconvulsive therapy versus transcranial magnetic stimulation for major depression: A review with recommendations for future research. Acta Neuropsychiatrica. 2008;20(6):291-4.
80 Rosenberg O, Shoenfeld N, Kotler M, Dannon PN. Mood disorders in elderly population: Neurostimulative treatment possibilities. Recent Patents on CNS Drug Discovery. 2009;4(2):149-55. [pmid: 19519563].
81 Rouillon F, Gorwood P. The use of lithium to augment antidepressant medication. J Clin Psychiatry. 5. 1998;59:32-9. discussion 40-1. [pmid: 9635546].
82 Rush AJ, Gullion CM, Roffwarg HP. When do patients respond to tricyclic antidepressants?. Biol Psychiatry. 1994;35:711-7.
83 Rush AJ, Kilner J, Fava M, Wisniewski SR, Warden D, Nierenberg AA, et al. Clinically relevant findings from STAR*D. Psychiatric Annals. 03. 2008;38(3):188-93.
84 Sackeim HA. Magnetic stimulation therapy and ECT. Convuls Ther. 1994;10(4):255-8.
85 Sackeim HA. Repetitive transcranial magnetic stimulation: What are the next steps?. Biological Psychiatry. 2000;48(10):959-61. [pmid: 11082468].
86 Sackeim HA. Memory and ECT: from polarization to reconciliation. J ECT. 2000;16(2):87-96. [pmid: 10868319].
87 Sakkas P, Mihalopoulou P, Mourtzouhou P, Psarros C, Masdrakis V, Politis A, et al. Induction of mania by rTMS: report of two cases. European Psychiatry. Jun. 2003;18(4):196-8. [pmid: 12814856].
88 Samaras N, Rossi G, Giannakopoulos P, Gold G. Vascular depression. An age-related mood disorder. European Geriatric Medicine. 2010;1(4):220-5.
89 Santos MA, Hara C, Stumpf BLP, Rocha FL. Treatment-resistant depression: Review of pharmacologic antidepressant strategies. Jornal Brasileiro de Psiquiatria. 2006;55(3):232-42.
90 Satel SL, Nelson JC. Stimulants in the treatment of depression: a critical overview. J Clin Psychiatry. Jul. 1989;50(7):241-9. [pmid: 2567730].
91 Schechter LE, Ring RH, Beyer CE, Hughes ZA, Khawaja X, Malberg JE, et al. Innovative approaches for the development of antidepressant drugs: current and future strategies. NeuroRx. Oct. 2005;2(4):590-611. [pmid: 16489368].
92 Schopf J. Treatment of depressions resistant to tricyclic antidepressants, related drugs or MAO-inhibitors by lithium addition: review of the literature. Pharmacopsychiatry. Sep. 1989;22(5):174-82. [pmid: 2682691].
93 Schramm E, Schneider D, Zobel I, van Calker D, Dykierek P, Kech S, et al. Efficacy of interpersonal psychotherapy plus pharmacotherapy in chronically depressed inpatients. Journal of Affective Disorders. Jul. 2008;109(1):65-73. [pmid: 18067973].
94 Schweitzer I, Tuckwell V, Johnson G. A review of the use of augmentation therapy for the treatment of resistant depression: implications for the clinician. Aust N Z J Psychiatry. Jun. 1997;31(3):340-52. [pmid: 9226079].
95 Scott J. Treatment of chronic depression. New England Journal of Medicine. 2000;342(20):1518-20. [pmid: 10816192].
96 Shelton RC. Mood-stabilizing drugs in depression. J Clin Psychiatry. 5. 1999;60:37-40. discussion 1-2. [pmid: 10192406].
97 Shelton RC. Treatment options for refractory depression. J Clin Psychiatry. 4. 1999;60:57-61. discussion 2-3. [pmid: 10086483].
98 Shelton RC, Papakostas GI. Augmentation of antidepressants with atypical antipsychotics for treatment-resistant major depressive disorder. Acta Psychiatr Scand. Apr. 2008;117(4):253-9. [pmid: 18190674].
99 Shuchman M. Approving the vagus-nerve stimulator for depression. New England Journal of Medicine. 2007;356(16):1604-7. [pmid: 17442903].
100 Small JG, Small IF. Electroconvulsive therapy update. Psychopharmacol Bull. Oct. 1981;17(4):29-42. [pmid: 6280228].
101 Sonawalla SB, Fava M. Severe depression: is there a best approach?. CNS Drugs. 2001;15(10):765-76. [pmid: 11602003].
102 Souery D, Amsterdam J, de Montigny C, Lecrubier Y, Montgomery S, Lipp O, et al. Treatment resistant depression: methodological overview and operational criteria. Eur Neuropsychopharmacol. Jan. 1999;9(1-2):83-91. [pmid: 10082232].
103 Souery D, Van der Auwera K. The multiple facets of treatment-resistant depression. CNS Spectr. Nov. 2004;9(11):803-7. [pmid: 15520604].
104 Spitzer RL, National Institute of Mental Health (U.S.). User's guide for the structured clinical interview for DSM-III-R: SCID. Washington, DC. American Psychiatric Press. 1990.
105 St John D. Pharmacotherapeutic approaches to treatment-resistant depression. Jaapa. Mar. 2003;16(3):32-4. 7. 8. 40 passim. [pmid: 14968524].
106 Standish-Barry H. Treating refractory depression. Int Clin Psychopharmacol. Jul. 3. 1990;5:33-43. [pmid: 2230071].
107 Stern SL, Mendels J. Drug combinations in the treatment of refractory depression: a review. J Clin Psychiatry. Oct. 1981;42(10):368-73. [pmid: 6116699].
108 Tanum LH. Combination treatment with antidepressants in refractory depression. Int Clin Psychopharmacol. Jun. 2. 1994;9:37-40. [pmid: 7930495].
109 Taylor D. Selective serotonin reuptake inhibitors and tricyclic antidepressants in combination. Interactions and therapeutic uses. Br J Psychiatry. Nov. 1995;167(5):575-80. [pmid: 8564311].
110 Thase ME Jr, Rush AJ Jr. Treatment-resistant depression, Treatment-Resistant Depression in Psychopharmacology: The Fourth Generation of Progress. 1995.
111 Thase ME. The need for clinically relevant research on treatment-resistant depression. J Clin Psychiatry. Apr. 2001;62(4):221-4. [pmid: 11379833].
112 Thase ME. Pharmacologic and therapeutic strategies in treatment-resistant depression. Augmentation strategies. CNS Spectr. Mar. 2009;14(3 Suppl 4):7-10. [pmid: 19407714].
113 Thase ME, Rush AJ. When at first you don't succeed: sequential strategies for antidepressant nonresponders. J Clin Psychiatry. 13. 1997;58:23-9. [pmid: 9402916].
114 Thomas SA, Lincoln NB. Factors relating to depression after stroke. Clinical Rehabilitation. 2004;18(5):589-90.
115 Tierney JG. Treatment-resistant depression: managed care considerations. J Manag Care Pharm. Jul. 2007;13(6 Suppl A):S2-7. [pmid: 17672818].
116 Tobin M. Psychopharmacology column: why choose selegiline transdermal system for refractory depression?. Issues Ment Health Nurs. Feb. 2007;28(2):223-8. [pmid: 17365170].
117 Tremblay P, Blier P. Catecholaminergic strategies for the treatment of major depression. Curr Drug Targets. Feb. 2006;7(2):149-58. [pmid: 16475956].
118 Triezenberg D, Vachon D, Helmen J, Schneider D. Clinical inquiries: How should you manage a depressed patient unresponsive to an SSRI. J Fam Pract. Dec. 2006;55(12):1081-2. 7. [pmid: 17137547].
119 Trimble MR. Worldwide use of clomipramine. J Clin Psychiatry. Aug. Suppl. 1990;51:51-4. discussion 5-8. [pmid: 2199435].
120 Trivedi MH. Treatment-resistant depression: new therapies on the horizon. Ann Clin Psychiatry. Mar. 2003;15(1):59-70. [pmid: 12839433].
121 Trivedi MH, Daly EJ. Treatment strategies to improve and sustain remission in major depressive disorder. Dialogues Clin Neurosci. 2008;10(4):377-84. [pmid: 19170395].
122 Trivedi MH, Lin EH, Katon WJ. Consensus recommendations for improving adherence, self-management, and outcomes in patients with depression. CNS Spectr. Aug. 2007;12(8 Suppl 13):1-27. [pmid: 17986951].
123 Unutzer J. Late-life depression. New England Journal of Medicine. 2007;357(22):2269-76. [pmid: 18046030].
124 Vanderhasselt MA, De Raedt R, Leyman L, Baeken C. Acute effects of repetitive transcranial magnetic stimulation on attentional control are related to antidepressant outcomes. J Psychiatry Neurosci. Mar. 2009;34(2):119-26. [pmid: 19270762].
125 Wager SG, Klein DF. Drug therapy strategies for treatment-resistant depression. Psychopharmacol Bull. 1988;24(1):69-74. [pmid: 3290951].
126 Warneke L. Managing resistant depression. When patients do not respond to therapy. Can Fam Physician. Apr. 1993;39:843-50. [pmid: 8495142].
127 Warneke L. Management of resistant depression. Can Fam Physician. Oct. 1996;42:1973-80. [pmid: 8894244].
128 Wells KB, Sturm R, Sherbourne CD, Meredith LS. Caring for Depression. Caring for Depression. 1996.
129 Wijeratne C, Sachdev P. Treatment-resistant depression: critique of current approaches. Aust N Z J Psychiatry. Sep. 2008;42(9):751-62. [pmid: 18696279].
130 Wilhelm K, Mitchell P, Boyce P, Hickie I, Brodaty H, Austin MP, et al. Treatment resistant depression in an Australian context. I: The utility of the term and approaches to management. Aust N Z J Psychiatry. Mar. 1994;28(1):14-22. [pmid: 7915106].
131 Williams GO. Management of depression in the elderly. Prim Care. Jun. 1989;16(2):451-74. [pmid: 2664841].
132 Woggon B. Methodology of measuring the efficacy of antidepressants--European viewpoint. Psychopharmacology (Berl). Suppl. 1992;106:S90-2. [pmid: 1546151].
133 Yip AG, Carpenter LL. Transcranial magnetic stimulation for medication-resistant depression. J Clin Psychiatry. Apr. 2010;71(4):502-3. [pmid: 20409447].
134 Young SN. Use of tryptophan in combination with other antidepressant treatments: a review. J Psychiatry Neurosci. Dec. 1991;16(5):241-6. [pmid: 1797098].
135 Zetin M, Hoepner CT, Bjornson L. Rational antidepressant selection: applying evidence-based medicine to complex real-world patients. Psychopharmacol Bull. 2006;39(1):38-104. [pmid: 17065974].
136 Zhang X, Liu K, Sun J, Zheng Z. Safety and feasibility of repetitive transcranial magnetic stimulation (rTMS) as a treatment for major depression during pregnancy. Arch Womens Ment Health. Aug. 2010;13(4):369-70. [pmid: 20386939].
137 Zullino D, Baumann P. Lithium augmentation in depressive patients not responding to selective serotonin reuptake inhibitors. Pharmacopsychiatry. Jul. 2001;34(4):119-27. [pmid: 11518471].

## Wrong Outcome

1 Agelink MW, Andrich J, Postert T, Wurzinger U, Zeit T, Klotz P, et al. Relation between electroconvulsive therapy, cognitive side effects, neuron specific enolase, and protein S-100. J Neurol Neurosurg Psychiatry. Sep. 2001;71(3):394-6. [pmid: 11511718].
2 Amiaz R, Stein O, Schreiber S, Danon PN, Dolberg OT, Grunhaus L. Magnetic and seizure thresholds before and after six electroconvulsive treatments. J Ect. Sep. 2001;17(3):195-7. [pmid: 11528311].
3 Babigian HM, Guttmacher LB. Epidemiologic considerations in electroconvulsive therapy. Arch Gen Psychiatry. Mar. 1984;41(3):246-53. [pmid: 6703844].
4 Baeken C, De Raedt R, Leyman L, Schiettecatte J, Kaufman L, Poppe K, et al. The impact of one HF-rTMS session on mood and salivary cortisol in treatment resistant unipolar melancholic depressed patients. J Affect Disord. Feb. 2009;113(1-2):100-8. [pmid: 18571733].
5 Baeken C, De Raedt R, Vanderhasselt MA, Leyman L, Schiettecatte J, Poppe K, et al. A “hypersensitive” hypothalamic-pituitaryadrenal system could be indicative for a negative clinical high-frequency repetitive transcranial magnetic stimulation outcome in melancholic depressed patients. Brain Stimulation. 2010:54-7.
6 Bajbouj M, Gallinat J, Lang UE, Neu P, Niehaus L. Motorcortical excitability after electroconvulsive therapy in patients with major depressive disorder. Suppl Clin Neurophysiol. 2003;56:433-40. [pmid: 14677419].
7 Bauer M, Bschor T, Kunz D, Berghofer A, Strohle A, Muller-Oerlinghausen B. Double-blind, placebo-controlled trial of the use of lithium to augment antidepressant medication in continuation treatment of unipolar major depression. The American Journal of Psychiatry. 09. 2000;157(9):1429-35. [pmid: 10964859].
8 Bosworth HB, McQuoid DR, George LK, Steffens DC. Time-to-remission from geriatric depression: psychosocial and clinical factors. Am J Geriatr Psychiatry. Sep-Oct. 2002;10(5):551-9. [pmid: 12213689].
9 Carpenter LL, Moreno FA, Kling MA, Anderson GM, Regenold WT, Labiner DM, et al. Effect of vagus nerve stimulation on cerebrospinal fluid monoamine metabolites, norepinephrine, and gamma-aminobutyric acid concentrations in depressed patients. Biological Psychiatry. Sep. 2004;56(6):418-26. [pmid: 15364040].
10 Chae JH, Nahas Z, Lomarev M, Denslow S, Lorberbaum JP, Bohning DE, et al. A review of functional neuroimaging studies of vagus nerve stimulation (VNS). Journal of Psychiatric Research. 2003;37(6):443-55. [pmid: 14563375].
11 Coffey CE, Weiner RD, Djang WT, Figiel GS, Soady SA, Patterson LJ, et al. Brain anatomic effects of electroconvulsive therapy. A prospective magnetic resonance imaging study. Arch Gen Psychiatry. Nov. 1991;48(11):1013-21. [pmid: 1747016].
12 Conca A, Peschina W, König P, Fritzsche H, Hausmann A. Effect of chronic repetitive transcranial magnetic stimulation on regional cerebral blood flow and regional cerebral glucose uptake in drug treatment-resistant depressives: A brief report. Neuropsychobiology. Jan. 2002;45(1):27-31. [pmid: 11803238].
13 Dang T, Avery DH, Russo J. Within-session mood changes from TMS in depressed patients. J Neuropsychiatry Clin Neurosci. Fall. 2007;19(4):458-63. [pmid: 18070851].
14 Dolberg OT, Dannon PN, Schreiber S, Grunhaus L. Magnetic motor threshold and response to TMS in major depressive disorder. Acta Psychiatrica Scandinavica. Sep. 2002;106(3):220-3. [pmid: 12197860].
15 Dunner DL, Rush AJ, Russell JM, Burke M, Woodard S, Wingard P, et al. Prospective, long-term, multicenter study of the naturalistic outcomes of patients with treatment-resistant depression. J Clin Psychiatry. May. 2006;67(5):688-95. [pmid: 16841617].
16 Eschweiler GW, Wegerer C, Schlotter W, Spandl C, Stevens A, Bartels M, et al. Left prefrontal activation predicts therapeutic effects of repetitive transcranial magnetic stimulation (rTMS) in major depression. Psychiatry Research: Neuroimaging. Oct. 2000;99(3):161-72.
17 Fitzgerald PB, Hoy K, McQueen S, Maller JJ, Herring S, Segrave R, et al. A randomized trial of rTMS targeted with MRI based neuro-navigation in treatment-resistant depression. Neuropsychopharmacology. Apr. 2009;34(5):1255-62. [pmid: 19145228].
18 Greenhalgh J, Knight C, Hind D, Beverley C, Walters S. Clinical and cost-effectiveness of electroconvulsive therapy for depressive illness, schizophrenia, catatonia and mania: systematic reviews and economic modelling studies. Health Technol Assess. Mar. 2005;9(9):1-156. iii. iv. [pmid: 15774232].
19 Grunhaus L, Hirschman S, Dolberg OT, Schreiber S, Dannon PN. Coadministration of melatonin and fluoxetine does not improve the 3-month outcome following ECT. J Ect. Jun. 2001;17(2):124-8. [pmid: 11417923].
20 Grunhaus L, Shipley JE, Eiser A, Pande AC, Tandon R, Remen A, et al. Shortened REM latency PostECT is associated with rapid recurrence of depressive symptomatology. Biol Psychiatry. Aug. 15. 1994;36(4):214-22. [pmid: 7986885].
21 Grunhaus L, Shipley JE, Eiser A, Pande AC, Tandon R, Remen A, et al. Polysomnographic studies in patients referred for ECT: pre-ECT studies. Convuls Ther. Dec. 1996;12(4):224-31. [pmid: 9034697].
22 Herbsman T, Avery D, Ramsey D, Holtzheimer P, Wadjik C, Hardaway F, et al. More lateral and anterior prefrontal coil location is associated with better repetitive transcranial magnetic stimulation antidepressant response. Biol Psychiatry. 2009/06/24. 2009:509-15.
23 Herwig U, Fallgatter AJ, Hoppner J, Eschweiler GW, Kron M, Hajak G, et al. Antidepressant effects of augmentative transcranial magnetic stimulation: randomised multicentre trial. Br J Psychiatry. Nov. 2007;191:441-8. [pmid: 17978325].
24 Kelway B, Simpson KH, Smith RJ, Halsall PJ. Effects of atropine and glycopyrrolate on cognitive function following anaesthesia and electroconvulsive therapy (ECT). Int Clin Psychopharmacol. Oct. 1986;1(4):296-302. [pmid: 3549875].
25 Lang UE, Hellweg R, Gallinat J, Bajbouj M. Acute prefrontal cortex transcranial magnetic stimulation in healthy volunteers: no effects on brain-derived neurotrophic factor (BDNF) concentrations in serum. J Affect Disord. Apr. 2008;107(1-3):255-8. [pmid: 17825920].
26 Lenox RH, Peyser JM, Rothschild B, Shipley J, Weaver L. Failure to normalize the dexamethasone suppression test: association with length of illness. Biol Psychiatry. Mar. 1985;20(3):333-7. [pmid: 3978166].
27 Lisanby SH, Husain MM, Rosenquist PB, Maixner D, Gutierrez R, Krystal A, et al. Daily left prefrontal repetitive transcranial magnetic stimulation in the acute treatment of major depression: clinical predictors of outcome in a multisite, randomized controlled clinical trial. Neuropsychopharmacology. Jan. 2009;34(2):522-34. [pmid: 18704101].
28 Luber B, Nobler MS, Moeller JR, Katzman GP, Prudic J, Devanand DP, et al. Quantitative EEG during seizures induced by electroconvulsive therapy: relations to treatment modality and clinical features. II. Topographic analyses. J Ect. Sep. 2000;16(3):229-43. [pmid: 11005044].
29 Munk-Olsen T, Laursen TM, Videbech P, Mortensen PB, Rosenberg R. All-cause mortality among recipients of electroconvulsive therapy: Register-based cohort study. British Journal of Psychiatry. 2007;190(MAY):435-9. [pmid: 17470959].
30 Murthy PJ, Gangadhar BN, Janakiramaiah N, Subbakrishna DK. Normalization of P300 amplitude following treatment in dysthymia. Biol Psychiatry. Oct. 15. 1997;42(8):740-3. [pmid: 9325569].
31 Nahas Z, Teneback C, Chae JH, Mu Q, Molnar C, Kozel FA, et al. Serial vagus nerve stimulation functional MRI in treatment-resistant depression. Neuropsychopharmacology. Aug. 2007;32(8):1649-60. [pmid: 17203016].
32 Navarro R, Zarkowski P, Sporn A, Avery D. Hemispheric asymmetry in resting motor threshold in major depression. J Ect. Mar. 2009;25(1):39-43. [pmid: 18580815].
33 Nelson AL, Cohen JT, Greenberg D, Kent DM. Much cheaper, almost as good: decrementally cost-effective medical innovation. Ann Intern Med. 2009/11/04. 2009:662-7.
34 O'Connor KP, Colter N, Shaw JC. Cognitive style, cortical function, and electroconvulsive therapy. J Nerv Ment Dis. Dec. 1984;172(12):711-7. [pmid: 6502149].
35 Pande AC, Grunhaus LJ, Aisen AM, Haskett RF. A preliminary magnetic resonance imaging study of ECT-treated depressed patients. Biol Psychiatry. Jan. 1. 1990;27(1):102-4. [pmid: 2297546].
36 Papakostas YG, Markianos M, Zervas IM, Theodoropoulou M, Vaidakis N, Daras M. Administration of citalopram before ECT: seizure duration and hormone responses. J Ect. Dec. 2000;16(4):356-60. [pmid: 11314873].
37 Prudic J, Fitzsimons L, Nobler MS, Sackeim HA. Naloxone in the prevention of the adverse cognitive effects of ECT: a within-subject, placebo controlled study. Neuropsychopharmacology. Aug. 1999;21(2):285-93. [pmid: 10432476].
38 Rapaport MH, Gharabawi GM, Canuso CM, Mahmoud RA, Keller MB, Bossie CA, et al. Effects of risperidone augmentation in patients with treatment-resistant depression: Results of open-label treatment followed by double-blind continuation. Neuropsychopharmacology. 2006/06/09. 2006:2505-13.
39 Rasmussen KG, Mueller M, Rummans TA, Husain MM, Petrides G, Knapp RG, et al. Is baseline medication resistance associated with potential for relapse after successful remission of a depressive episode with ECT? Data from the Consortium for Research on Electroconvulsive Therapy (CORE). J Clin Psychiatry. Feb. 2009;70(2):232-7. [pmid: 19192459].
40 Rasmussen KG, Stevens SR, Kung S, Mohan A. Melancholic symptoms as assessed by the Hamilton Depression Rating Scale and outcomes with and without electroconvulsive therapy on an in-patient mood disorders unit. Acta Neuropsychiatrica. 2010;22(1):21-5.
41 Recart A, Rawal S, White PF, Byerly S, Thornton L. The effect of remifentanil on seizure duration and acute hemodynamic responses to electroconvulsive therapy. Anesth Analg. Apr. 2003;96(4):1047-50. table of contents. [pmid: 12651657].
42 Rohland BM. Self-report of improvement following hospitalization for electroconvulsive therapy: relationship to functional status and service use. Adm Policy Ment Health. Jan. 2001;28(3):193-203. [pmid: 11330015].
43 Saravanan ES, Gangadhar BN, Janakiramaiah N, Pandey RS, Murthy HS, Subbakrishna DK. Does higher cardiovascular response to ECT predict early antidepressant effect?. J Affect Disord. May. 2002;69(1-3):101-8. [pmid: 12103457].
44 Sawayama E, Takahashi M, Inoue A, Nakajima K, Kano A, Sawayama T, et al. Moderate hyperventilation prolongs electroencephalogram seizure duration of the first electroconvulsive therapy. J Ect. Sep. 2008;24(3):195-8. [pmid: 18772703].
45 Scott AI, Boddy H. The effect of repeated bilateral electroconvulsive therapy on seizure threshold. J Ect. Sep. 2000;16(3):244-51. [pmid: 11005045].
46 Simpson S, Baldwin RC, Jackson A, Burns AS. Is subcortical disease associated with a poor response to antidepressants? Neurological, neuropsychological and neuroradiological findings in late-life depression. Psychol Med. Sep. 1998;28(5):1015-26. [pmid: 9794009].
47 Stern RA, Nevels CT, Shelhorse ME, Prohaska ML, Mason GA, Prange AJ Jr. Antidepressant and memory effects of combined thyroid hormone treatment and electroconvulsive therapy: preliminary findings. Biol Psychiatry. Sep. 15. 1991;30(6):623-7. [pmid: 1932410].
48 Swan J, Sorrell E, MacVicar B, Durham R, Matthews K. “Coping with depression”: an open study of the efficacy of a group psychoeducational intervention in chronic, treatment-refractory depression. J Affect Disord. Oct. 1. 2004;82(1):125-9. [pmid: 15465585].
49 Tang WK, Ungvari GS, Leung HC. Effect of piracetam on ECT-induced cognitive disturbances: a randomized, placebo-controlled, double-blind study. J Ect. Sep. 2002;18(3):130-7. [pmid: 12394531].
50 Van HL, Dekker J, Peen J, van Aalst G, Schoevers RA. Identifying patients at risk of complete nonresponse in the outpatient treatment of depression. Psychother Psychosom. 2008;77(6):358-64. [pmid: 18701832].
51 Wilkinson P, Hawton K, Andrew B, Fagg J. Does the duration of illness before treatment affect the time taken to recover on treatment in severely depressed women?. J Affect Disord. Nov. 25. 1996;41(2):89-92. [pmid: 8961035].
52 Yukimasa T, Yoshimura R, Tamagawa A, Uozumi T, Shinkai K, Ueda N, et al. High-frequency repetitive transcranial magnetic stimulation improves refractory depression by influencing catecholamine and brain-derived neurotrophic factors. Pharmacopsychiatry. Mar. 2006;39(2):52-9. [pmid: 16555165].
53 Zubenko GS, Mulsant BH, Rifai AH, Sweet RA, Pasternak RE, Marino LJ Jr, et al. Impact of acute psychiatric inpatient treatment on major depression in late life and prediction of response. Am J Psychiatry. Jul. 1994;151(7):987-94. [pmid: 8010384].

## Published Prior to 1980

1 Abrams R, DeVito RA. Clinical efficacy of unilateral ECT. Diseases of the nervous system. 1969;30(4):262-3. [pmid: 4890011].
2 Avery D, Winokur G. Mortality in depressed patients treated with electroconvulsive therapy and antidepressants. Archives of General Psychiatry. 1976;33(9):1029-37. [pmid: 962487].
3 Barton JL, Mehta S, Snaith RP. The prophylactic value of extra ECT in depressive illness. Acta Psychiatrica Scandinavica. 1973;49(4):386-92. [pmid: 4746007].
4 Bidder TG, Strain JJ, Brunschwig L. Bilateral and unilateral ECT: follow-up study and critique. American Journal of Psychiatry. 1970;127(6):737-45. [pmid: 5482867].
5 Bratfos O, Haug JO. Electroconvulsive therapy and antidepressant drugs in manic-depressive disease. Treatment results at discharge and 3 months later. Acta Psychiatrica Scandinavica. 1965;41(4):588-96. [pmid: 5884008].
6 Bruce EM, Crone N, Fitzpatrick G, Frewin SJ, Gillis A, Lascelles CF, et al. A comparative trial of ECT and tofranil. American Journal of Psychiatry. 1960;117:76. [pmid: 13805124].
7 Carney MW, Rogan PA, Sebastian J, Sheffield B. A controlled comparative trial of unilateral and bilateral sinusoidal and pulse E.C.T. in endogenous depression. Physicians' Drug Manual. 1976;7:9-128/1.
8 Costello CG, Belton GP, Abra JC, Dunn BE. The amnesic and therapeutic effects of bilateral and unilateral ECT. British Journal of Psychiatry. 1970;116(530):69-78. [pmid: 5411010].
9 Davidson J, McLeod M, Law-Yone B. A comparison of electroconvulsive therapy and combined phenelzine-amitriptyline in refractory depression. Archives of General Psychiatry. 1978;35(5):639-42. [pmid: 727903].
10 D'Elia G. Comparison of electroconvulsive therapy with unilateral and bilateral stimulation, II: Therapeutic efficacy in endogenous depression. Acta Psychiatr Scand. 1970;215:30-43.
11 D'Elia G. Comparison of electroconvulsive therapy with unilateral and bilateral stimulation, III: Anterograde amnesia. Acta Psychiatr Scand Suppl. 1970;212:44-60. [pmid: 4917971].
12 Fleminger JJ, de Horne DJ, Nair NP, Nott PN. Differential effect of unilateral and bilateral ECT. American Journal of Psychiatry. 1970;127(4):430-6. [pmid: 4918113].
13 Freeman CPL, Basson JV, Crighton A. Double-blind controlled trial of electroconvulsive therapy (E.C.T.) and simulated E.C.T. in depressive illness. Lancet. 1978;1(8067):738-40. [pmid: 76748].
14 Fromholt P, Christensen AL, Sand Stromgren L. The effects of unilateral and bilateral electroconvulsive therapy on memory. Acta Psychiatrica Scandinavica. 1973;49(4):466-78. [pmid: 4746012].
15 Halliday AM, Davison K, Browne MW, Kreeger LC. A comparison of the effects on depression and memory of bilateral E.C.T. and unilateral E.C.T. to the dominant and non-dominant hemispheres. British Journal of Psychiatry. 1968;114(513):997-1012. [pmid: 4879296].
16 Herrington RN, Bruce A, Johnstone EC, Lader MH. Comparative trial of L tryptophan and E.C.T. in severe depressive illness. Lancet. 1974;2(7883):731-4. [pmid: 4143007].
17 Heshe J, Röder E, Theilgaard A. Unilateral and bilateral ECT. A psychiatric and psychological study of therapeutic effect and side effects. Acta Psychiatrica Scandinavica, Supplement. 1978;(275):1-180.
18 Hutchinson J, Smedberg D. Treatment of depression: A comparative study of ECT and six drugs. Br J Psychiatry. 1963;109:536-8. [pmid: 13955929].
19 Levy R. The clinical evaluation of unilateral electroconvulsive therapy. British Journal of Psychiatry. 1968;114(509):459-63. [pmid: 5656265].
20 Mandel MR, Welch CA, Mieske M. Prediction of response to ECT in tricyclic-intolerant or tricyclic-resistant depressed patients. McLean Hosp J. 1977;4:203-9.
21 McDonald IM, Perkins M, Marjerrison G, Podilsky M. A controlled comparison of amitriptyline and electroconvulsive therapy in the treatment of depression. American Journal of Psychiatry. 1966;122(12):1427-31. [pmid: 5326021].
22 Robin A, Harris JA. A controlled comparison of imipramine and electroplexy. J Ment Sci. 1962;108:217-9. [pmid: 14492854].
23 Stanley W, Fleming H. A clinical comparison of phenelzine and electroconvulsive therapy in the treatment of depressive illness. Br J Psychiatry. 1962;108:708-10.
24 Steiner M, Radwan M, Elizur A. Failure of L-triiodothyronine (T3) to potentiate tricyclic antidepressant response. Current Therapeutic Research - Clinical and Experimental. 1978;23(5 II):655-9.
25 Strömgren LS. Unilateral versus bilateral electroconvulsive therapy. Investigations into the therapeutic effect in endogenous depression. Acta Psychiatrica Scandinavica, Supplement. 1973;240:8-65.
26 Thiery M. Clinical trial of the treatment of depressive illness. BMJ. 1965;1:881-6. [pmid: 14257398].
27 Wilson IC, Vernon JT, Guin T. A controlled study of treatments of depression. J Neuropsychiatry. 1963;4:331-7.

## Wrong Intervention

1 Asnis GM, Halbreich U, Nathan RS, Ostrow L, Novacenko H, Endicott J, et al. The dexamethasone suppression test in depressive illness: clinical correlates. Psychoneuroendocrinology. 1982;7(4):295-301. [pmid: 6820157].
2 Bosworth HB, Hays JC, George LK, Steffens DC. Psychosocial and clinical predictors of unipolar depression outcome in older adults. Int J Geriatr Psychiatry. Mar. 2002;17(3):238-46. [pmid: 11921152].
3 Cassidy F, Weiner RD, Cooper TB, Carroll BJ. Combined catecholamine and indoleamine depletion following response to ECT. British Journal of Psychiatry. June. 2010;196(6):493-4. [pmid: 20513863].
4 Cooper-Kazaz R, Lerer B. Efficacy and safety of triiodothyronine supplementation in patients with major depressive disorder treated with specific serotonin reuptake inhibitors. Int J Neuropsychopharmacol. Aug. 2008;11(5):685-99. [pmid: 18047754].
5 Coppen A. Lithium in unipolar depression and the prevention of suicide. J Clin Psychiatry. 9. 2000;61:52-6. [pmid: 10826662].
6 Fregni F, Marcolin MA, Myczkowski M, Amiaz R, Hasey G, Rumi DO, et al. Predictors of antidepressant response in clinical trials of transcranial magnetic stimulation. Int J Neuropsychopharmacol. Dec. 2006;9(6):641-54. [pmid: 16939662].
7 Huber R, MÃ¤Ã¤ttÃ¤ S, Esser SK, Sarasso S, Ferrarelli F, Watson A, et al. Measures of cortical plasticity after transcranial paired associative stimulation predict changes in electroencephalogram slow-wave activity during subsequent sleep. Journal of Neuroscience. Jul. 2008;28(31):7911-8. [pmid: 18667623].
8 Kennedy N, Paykel ES. Treatment and response in refractory depression: results from a specialist affective disorders service. J Affect Disord. Jul. 2004;81(1):49-53. [pmid: 15183599].
9 Kirov G, Ebmeier KP, Scott AI, Atkins M, Khalid N, Carrick L, et al. Quick recovery of orientation after magnetic seizure therapy for major depressive disorder. Br J Psychiatry. Aug. 2008;193(2):152-5. [pmid: 18670002].
10 Lauritzen L, Odgaard K, Clemmesen L, Lunde M, Ohrstrom J, Black C, et al. Relapse prevention by means of paroxetine in ECT-treated patients with major depression: a comparison with imipramine and placebo in medium-term continuation therapy. Acta Psychiatr Scand. Oct. 1996;94(4):241-51. [pmid: 8911559].
11 Li X, Nahas Z, Kozel FA, Anderson B, Bohning DE, George MS. Acute left prefrontal transcranial magnetic stimulation in depressed patients is associated with immediately increased activity in prefrontal cortical as well as subcortical regions. Biol Psychiatry. May. 1. 2004;55(9):882-90. [pmid: 15110731].
12 Mathew SJ, Murrough JW, aan het Rot M, Collins KA, Reich DL, Charney DS. Riluzole for relapse prevention following intravenous ketamine in treatment-resistant depression: A pilot randomized, placebo-controlled continuation trial. International Journal of Neuropsychopharmacology. 2010;13(1):71-82. [pmid: 19288975].
13 Mayur PM, Gangadhar BN, Subbakrishna DK, Janakiramaiah N. Discontinuation of antidepressant drugs during electroconvulsive therapy: a controlled study. J Affect Disord. Apr. 2000;58(1):37-41. [pmid: 10760556].
14 Mizrak A, Koruk S, Ganidagli S, Bulut M, Oner U. Premedication with dexmedetomidine and midazolam attenuates agitation after electroconvulsive therapy. Journal of Anesthesia. 2009;23(1):6-10. [pmid: 19234815].
15 Neuhaus AH, Gallinat J, Bajbouj M, Reischies FM. Interictal slow-wave focus in left medial temporal lobe during bilateral electroconvulsive therapy. Neuropsychobiology. 2005;52(4):183-9. [pmid: 16220024].
16 O'Reardon JP, Chopra MP, Bergan A, Gallop R, DeRubeis RJ, Crits-Christoph P. Response to tryptophan depletion in major depression treated with either cognitive therapy or selective serotonin reuptake inhibitor antidepressants. Biol Psychiatry. May. 1. 2004;55(9):957-9. [pmid: 15110741].
17 Rocha FL, Hara C. Lamotrigine augmentation in unipolar depression. Int Clin Psychopharmacol. Mar. 2003;18(2):97-9. [pmid: 12598821].
18 Rush AJ, Trivedi MH, Wisniewski SR, Nierenberg AA, Stewart JW, Warden D, et al. Acute and longer-term outcomes in depressed outpatients requiring one or several treatment steps: A STAR*D report. American Journal of Psychiatry. 2006;163(11):1905-17. [pmid: 17074942].
19 Santos MA, Rocha FL, Hara C. Efficacy and safety of antidepressant augmentation with lamotrigine in patients with treatment-resistant depression: A randomized, placebo-controlled, double-blind study. Primary Care Companion to the Journal of Clinical Psychiatry. 2008;10(3):187-90.
20 Schlaepfer TE, Cohen MX, Frick C, Kosel M, Brodesser D, Axmacher N, et al. Deep brain stimulation to reward circuitry alleviates anhedonia in refractory major depression. Neuropsychopharmacology. Jan. 2008;33(2):368-77. [pmid: 17429407].
21 Shajahan PM, Glabus MF, Jenkins JA, Ebmeier KP. Postexercise motor evoked potentials in depressed and recovered depressed patients, and controls. Neurology. Aug. 1999;53(3):644-6. [pmid: 10449139].
22 Shapira B, Oppenheim G, Zohar J, Segal M, Malach D, Belmaker RH. Lack of efficacy of estrogen supplementation to imipramine in resistant female depressives. Biol Psychiatry. May. 1985;20(5):576-9. [pmid: 2985131].
23 Small JG, Kellams JJ, Dennis JL, Milstein V. Comparison of molindone and tranylcypromine in the treatment of refractory depression. J Clin Pharmacol. Aug-sep. 1981;21(8-9):351-8. [pmid: 7276229].
24 Sobiś J, Jarząb M, Hese RT, Sieroń A, Zyss T, Gorczyca P, et al. Therapeutic efficacy assessment of weak variable magnetic fields with low value of induction in patients with drug-resistant depression. Journal of Affective Disorders. 2010;123(1-3):321-6. [pmid: 19896204].
25 Teodor Hese R, Jedrzejewska B. Multiple EEG examinations in patients with recurrent, refractory major depression and bipolar depression after course of UECT. Archives of Psychiatry and Psychotherapy. Sep. 2000;2(3):17-24.
26 Thase ME, Greenhouse JB, Frank E, Reynolds CF 3rd, Pilkonis PA, Hurley K, et al. Treatment of major depression with psychotherapy or psychotherapy-pharmacotherapy combinations. Arch Gen Psychiatry. Nov. 1997;54(11):1009-15. [pmid: 9366657].
27 Trivedi MH, Rush AJ, Crismon ML, Kashner TM, Toprac MG, Carmody TJ, et al. Clinical results for patients with major depressive disorder in the Texas Medication Algorithm Project. Arch Gen Psychiatry. Jul. 2004;61(7):669-80. [pmid: 15237079].
28 Williams MD, Rummans T, Sampson S, Knapp R, Mueller M, Husain MM, et al. Outcome of electroconvulsive therapy by race in the Consortium for Research on Electroconvulsive Therapy multisite study. J Ect. Jun. 2008;24(2):117-21. [pmid: 18580553].
29 Zhang Y, White PF, Thornton L, Perdue L, Downing M. The use of nicardipine for electroconvulsive therapy: a dose-ranging study. Anesth Analg. Feb. 2005;100(2):378-81. [pmid: 15673861].

## Wrong Study Design

1 Amsterdam JD, Garcia-Espana F, Rosenzweig M. Clomipramine augmentation in treatment-resistant depression. Depress Anxiety. 1997;5(2):84-90. [pmid: 9262938].
2 Bares M, Novak T, Kopecek M, Stopkova P, Sos P. Is combined treatment more effective than switching to monotherapy in patients with resistant depression? A retrospective study. Neuro Endocrinol Lett. 2009;30(6):723-8. [pmid: 20038931].
3 Black DW, Goldstein RB, Nasrallah A, Winokur G. The prediction of recovery using a multivariate model in 1471 depressed inpatients. Eur Arch Psychiatry Clin Neurosci. 1991;241(1):41-5. [pmid: 1832304].
4 Bouwer C, Stein DJ. Buspirone is an effective augmenting agent of serotonin selective re-uptake inhibitors in severe treatment-refractory depression. S Afr Med J. Apr. 1987;87(4 Suppl):534-7. 40. [pmid: 9180827].
5 Fontaine R, Ontiveros A, Elie R, Vezina M. Lithium carbonate augmentation of desipramine and fluoxetine in refractory depression. Biol Psychiatry. May. 1. 1991;29(9):946-8. [pmid: 1904782].
6 George MS, Rush AJ, Marangell LB, Sackeim HA, Brannan SK, Davis SM, et al. A one-year comparison of vagus nerve stimulation with treatment as usual for treatment-resistant depression. Biol Psychiatry. Sep. 1. 2005;58(5):364-73. [pmid: 16139582].
7 Ivanova JI, Birnbaum HG, Kidolezi Y, Subramanian G, Khan SA, Stensland MD. Direct and indirect costs of employees with treatment-resistant and non-treatment-resistant major depressive disorder. Current Medical Research and Opinion. 2010;26(10):2475-84. [pmid: 20825269].
8 Janssen J, Pol HEH, Schnack HG, Kok RM, Lampe IK, de Leeuw FE, et al. Cerebral volume measurements and subcortical white matter lesions and short-term treatment response in late life depression. International Journal of Geriatric Psychiatry. 05. 2007;22(5):468-74. [pmid: 17357181].
9 Kalayam B, Alexopoulos GS. Prefrontal dysfunction and treatment response in geriatric depression. Archives of General Psychiatry. 08. 1999;56(8):713-8. [pmid: 10435605].
10 Nierenberg AA, Papakostas GI, Petersen T, Kelly KE, Iacoviello BM, Worthington JJ, et al. Nortriptyline for treatment-resistant depression. J Clin Psychiatry. Jan. 2003;64(1):35-9. [pmid: 12590621].
11 Patten SB, Lupin DA, Boucher SA, Lamarre CJ. Pharmacologic management of refractory depression. Cmaj. Feb. 15. 1992;146(4):483-7. [pmid: 1737312].
12 Trivedi MH, Kleiber BA. Using treatment algorithms for the effective management of treatment-resistant depression. J Clin Psychiatry. 18. 2001;62:25-9. [pmid: 11575732].
13 Trivedi MH, Thase ME, Osuntokun O, Henley DB, Case M, Watson SB, et al. An integrated analysis of olanzapine/fluoxetine combination in clinical trials of treatment-resistant depression. J Clin Psychiatry. Mar. 2009;70(3):387-96. [pmid: 19284928].
14 Walter G, Martin J, Kirkby K, Pridmore S. Transcranial magnetic stimulation: experience, knowledge and attitudes of recipients. Aust N Z J Psychiatry. Feb. 2001;35(1):58-61. [pmid: 11270457].
15 Wijkstra J, Nolen WA, Algra A, van Vliet IM, Kahn RS. Relapse prevention in major depressive disorder after successful ECT: a literature review and a naturalistic case series. Acta Psychiatr Scand. Dec. 2000;102(6):454-60. [pmid: 11142436].