# Data Abstraction Forms

Inclusion/Exclusion Criteria for Abstract Review

Inclusion/Exclusion Criteria for Full Text Review

## Internal Validity Quality Forms

Quality for Experimental Studies

Quality Review for Observational Studies